# 1 OVERVIEW OF BACKGROUND INFORMATION AND ASSESSMENT METHODS

A series of five PFAS assessments (PFBA, perfluorohexanoic acid [PFHxA], perfluorohexane sulfonate [PFHxS], perfluorononanoic acid [PFNA], perfluorodecanoic acid [PFDA], and their associated salts; (see December 2018 IRIS Outlook (https://www.epa.gov/sites/production/files/2018-12/documents/iris_program_outlook_december_2018.pdf)) is being developed by the Integrated Risk Information System (IRIS) Program at the request of the U.S. Environmental Protection Agency (EPA) national programs and regions. Appendix A is the systematic review protocol for these five PFAS assessments. The protocol outlines the scoping and problem formulation efforts relating to these assessments, including a summary of other federal and state reference values for PFBA. The protocol also lays out the systematic review and dose-response methods used to conduct this review (see also Section 1.2). This systematic review protocol was released for public comment in November 2019 and was subsequently updated on the basis of those public comments. Appendix A includes the updated version of the protocol, including a summary of the updates in the protocol history section (see Appendix A, Section 12).

## 1.1 BACKGROUND INFORMATION ON PERFLUOROBUTANOIC ACID (PFBA)

Section 1.1 provides a brief overview of aspects of the physicochemical properties, human exposure, and environmental fate characteristics of perfluorobutanoic acid (PFBA, CASRN 375-22-4) and its related salt ammonium perfluorobutanoate (NH_4_^+^ PFB, CASRN 10495-86-0) that might provide useful context for this assessment. This overview is not intended to provide a comprehensive description of the available information on these topics. The reader is encouraged to refer to source materials cited below, more recent publications on these topics, and the assessment systematic review protocol (see Appendix A).

### 1.1.1 Physical and Chemical Properties

PFBA and its related salts are members of the group of per- and polyfluoroalkyl substances (PFAS). Concerns about PFBA and other PFAS stem from the resistance of these compounds to hydrolysis, photolysis, and biodegradation, which leads to their persistence in the environment (Sundström et al., 2012). The specific chemical formula of PFBA is C_4_HF_7_O_2_ and the chemical formula of NH_4_^+^PFB is C_4_H_4_F_7_NO_2_. More specifically, these PFAS are classified as perfluoroalkyl carboxylic acids [PFCAs; OECD (2018)]. Because PFBA and NH_4_^+^PFB are PFCAs containing less than seven perfluorinated carbon groups, they are considered short-chain PFAS. The specific chemical formula of PFBA is C_4_HF_7_O_2_ and the chemical formula of NH_4_^+^PFB is C_4_H_4_F_7_NO_2_. More specifically, these PFAS are classified as perfluoroalkyl carboxylic acids [PFCAs; OECD (2018)]. Because PFBA and NH_4_^+^PFB are PFCAs containing less than seven perfluorinated carbon groups, they are considered short-chain PFAS (ATSDR, 2018a). The chemical structures of PFBA and NH_4_^+^PFB are presented in Figure 1-1, and select physicochemical properties are provided in Table 1-1.

Figure 1-1 Chemical structures of perfluorobutanoic acid (PFBA) and ammonium perfluorobutanoate (NH_4_^+^PFB)

Table 1-1 Predicted or experimental physicochemical properties of perfluorobutanoic acid (PFBA; CASRN 375-22-4) and ammonium perfluorobutanoate (NH_4_^+^PFB; CASRN 10495-86-0)

Property (unit) | Value
Property (unit) | PFBA (free acid) | NH_4_^+^PFB
Molecular weight (g/mol) | 214^a^ | 231^a^
Melting point (°C) | −17.5^a^ | ND
Boiling point (°C) | 121^a^ | ND
Density (g/cm^3^) | 1.65^a^ | ND
Vapor pressure (mm Hg) | 6.37^a^ | ND
Henry’s law constant (atm-m^3^/mole) | 4.99 × 10^−5a,^ ^b^ | ND
Water solubility (mol/L) | 2.09 × 10^−3a^ | ND
PKa | 0.08^b,^ ^c^ | ND
Octanol-water partition coefficient (Log Kow) | 1.43^a^ | ND
Soil adsorption coefficient (L/kg) | 88.9^a,^ ^b^ | ND
Bioconcentration factor (BCF) | 6.67^a,b^ | ND

ND = no data.

a U.S. EPA (2018a) Chemicals Dashboard (PFBA DTXSID: 4059916): ^a^U.S. EPA (2018a) Chemicals Dashboard (PFBA DTXSID: 4059916): https://comptox.epa.gov/dashboard/dsstoxdb/results?utf8=%E2%9C%93&search=375-22-4. Median or average experimental values used where available; otherwise, median, or average predicted values used to depend on which was available.

b Predicted.

c ATSDR (2018a).

### 1.1.2 Sources, Production, and Use

PFAS are not naturally occurring in the environment (ATSDR, 2018a). They are synthetic compounds that are or have been used widely over the past several decades in consumer products and industrial applications because of their resistance to heat, oil, stains, grease, and water. PFBA is a breakdown product of other PFAS used in stain-resistant fabrics, paper food packaging, and carpets; it was also used for manufacturing photographic film (MDH, 2017). Shorter-chain PFAS like PFBA are also being used as substitutes for longer chain PFAS in consumer products (Liu et al., 2014). Kotthoff et al. (2015) analyzed a variety of consumer products for PFAS. PFBA was detected in nano- and impregnation-sprays, outdoor textiles, carpets, gloves, paper-based food contact materials, ski wax, and leather.

The U.S. Environmental Protection Agency (EPA) has been working with companies in the fluorochemical industry since the early 2000s to phase out the production and use of long-chain PFAS [ATSDR (2018a) https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-PFAS] (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-pfass). The production and use of these chemicals, however, have resulted in their release to the environment through various waste streams (NLM, 2016, 2013). Also, because products containing PFAS are still in use, they could continue to be a source of environmental contamination due to disposal or breakdown in the environment (Kim and Kannan, 2007).

No Chemical Data Reporting (CDR) on production volume for PFBA or its salts are available in EPA’s ChemView (U.S. EPA, 2019a). Also, because facilities manufacturing, processing, or otherwise using PFAS are not required to report on releases to the environment, no quantitative information on PFBA is available in EPA’s Toxic Release Inventory [TRI (U.S. EPA, 2019a)].^6^

Wang et al. (2014) estimated global emission estimates of PFBA from direct and indirect (i.e., degradation of precursors) sources between 1951 and 2030 to be between 15 and 915 metric tons. The lower estimate assumes that producers cease production and use of long-chain PFCAs and their precursors in line with global transition trends. The higher estimate assumes the emission scenario in 2015 remains constant until 2030.

### 1.1.3 Environmental Fate and Transport

PFAS are stable and persistent in the environment (ATSDR, 2018a; NLM, 2017, 2016, 2013) and many are found worldwide in the air, soil, groundwater, and surface water, and in the tissues of plants and animals (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-PFAS (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-pfass)).

PFAS released to air exist in the vapor phase in the atmosphere and resist photolysis, but particle-bound concentrations also have been measured (NLM, 2017, 2016, 2013; Kim and Kannan, 2007). Wet and dry deposition are potential removal processes for particle-bound PFAS in air (ATSDR, 2018b; Barton et al., 2007; Prevedouros et al., 2006; Hurley et al., 2004). Vapor intrusion may be a concern for PFBA given its vapor pressure and Henry’s law constant, although no data currently exist measuring inhalation exposures due to vapor intrusion of PFBA.

PFBA would not be expected to be mobile in soil based on its soil adsorption coefficient (see Table 1-1). Zhao et al. (2016) observed that shorter chain PFAS like PFBA were transported more readily from the roots to the shoots of wheat plants than longer chain PFAS. Venkatesan and Halden (2014) analyzed archived samples from outdoor mesocosms to investigate the fate over 3 years of PFAS in agricultural soil amended with biosolids. The mean half-life for loss of PFBA from soils following biosolid application was estimated to be 385 days. PFBA would not be expected to be mobile in soil based on its soil adsorption coefficient (see Table 1-1).

The potential for PFAS to bioconcentrate in aquatic organisms depends on their bioconcentration factors (see Table 1-1), with longer chain PFAS accumulating to a greater degree. Thus, the potential for PFBA to bioconcentrate is low compared with other PFAS (bioconcentration factor of 7.61 vs. 789 and 752 for perfluorodecanoic acid [PFDA] and perfluorononanoic acid [PFNA], respectively). PFBA has been found to bioaccumulate in foods grown on PFAS-containing soil. Blaine et al. (2013) conducted a series of greenhouse and field experiments to investigate the potential for PFAS to be taken up by lettuce, tomatoes, and corn when grown in industrially impacted biosolids-amended soil and municipal biosolids-amended soil. PFBA was found to bioaccumulate more readily than other PFAS (e.g., PFOA, PFOS, PFHxA, PFHxS, PFDA, and PFNA) with bioaccumulation factors of 28.4−56.8 for lettuce and 68.4 for corn. PFBA had a bioaccumulation factor of 12.2−18.2 for tomatoes, which was higher than all other PFAS studied except perfluoropentanoic acid (bioaccumulation factor of 14.9–17.1).

PFBA has not been evaluated under the National Air Toxics Assessment program (https://www.epa.gov/national-air-toxics-assessment). Likewise, although EPA conducted monitoring for several PFAS in drinking water as part of the third Unregulated Contaminant Monitoring Rule [UCMR; U.S. EPA (2019b)], PFBA was not among the 30 contaminants monitored.

PFBA can be detected in most dust samples obtained from U.S. homes and vehicles, however, and has been measured at higher levels in the soil and sediment surrounding perfluorochemical industrial facilities, at U.S. military facilities, and at training grounds where aqueous film-forming foam (AFFF) has been used for fire suppression (see Appendix A, Section 2.1). PFBA also has been measured in the surface water and groundwater at military installations, AFFF training grounds, and industrial sites, although data are sparse. PFBA levels in water at these sites seem to exceed those identified in drinking water (see Appendix A, Section 2.1).

PFBA also can be detected in food. PFBA has been found in fish at 16% of sites sampled in the U.S. Great Lakes (maximum concentration 1.3 ng/g) (Stahl et al., 2014). Additionally, although most of the available data are from samples from outside the U.S., PFBA has been detected in grocery items including dairy products, meats and seafood, fruits and vegetables, food packaging, and spices (see Appendix A, Section 2.1).

Specifically, regarding drinking water, PFBA concentrations ranged from 0.0855 to 2.04 µg/L in seven municipal wells in Oakdale, Minnesota (U.S. EPA, 2019a). In a study of 23 public water systems in New Jersey (out of over 1,000), only 3% of raw water samples contained PFBA, and did so at concentrations much less than those reported in Minnesota [range from nondetectable to 0.006 µg/L; (Post et al., 2013)]. Heo et al. (2014) detected PFBA in tap water and bottled water in Korea at mean concentrations of 2.02 and 0.039 ng/L, respectively. The concentrations of PFBA measured at National Priorities List (NPL) sites are provided in Table 1-2 ]. Heo et al. (2014) detected PFBA in tap water and bottled water in Korea at mean concentrations of 2.02 and 0.039 ng/L, respectively. The concentrations of PFBA measured at National Priorities List (NPL) sites are provided in Table 1-2 (ATSDR, 2017).

Table 1-2 Perfluorobutanoic acid (PFBA) levels in water, soil, and air at National Priority List (NPL) sites

Media | Value | Number of NPL sites with detections
Water (ppb)
Median | 2.15 | 3
Geometric mean | 1.03
Soil (ppb)
Median | 1,600 | 2
Geometric mean | 1,600
Air (ppbv)
Median | ND
Geometric mean | ND

ND = No data.

Source: ATSDR (2017).

### 1.1.4 Potential for Human Exposure and Populations with Potentially Greater Exposure

The general population could be exposed to PFAS via inhalation of indoor or outdoor air (with PFAS possibly being released to the atmosphere via manufacturing processes or via disposal, i.e., incineration), ingestion of drinking water and food, and dermal contact with PFAS-containing products (ATSDR, 2018a). Exposure might also occur via hand-to-mouth transfer of materials containing these compounds (ATSDR, 2018a). The oral route of exposure has been considered the most important one among the general population, however (Klaunig et al., 2015). Contaminated drinking water is likely to be a significant source of exposure. Due to the moderate water solubility and mobility of PFAS in groundwater (and general lack of remediation technology at water treatment facilities), populations consuming drinking water from any contaminated watershed could be exposed to PFAS (Sun et al., 2016). Use of powdered granulated carbon is more efficient in removing longer-chain PFAS (Sun et al., 2016). Gebbink et al. (2015) modeled exposure to PFBA among the adult general population using a number of exposure scenarios based on the 5th, median, and 95th percentiles of all input exposure parameters. “Intermediate” exposure (i.e., based on median inputs for all exposure parameters) from direct and indirect (i.e., precursor) sources was estimated to be 19 pg/kg-day. Of the pathways evaluated (i.e., ingestion of dust, food, water; inhalation of air), direct intake of PFBA in water accounted for the largest portion (approximately 90%−100%) of total exposure for all three exposure scenarios considered.

Several PFAS have been monitored in the human population as part of the National Health and Nutrition Examination Survey [NHANES; CDC (2019)], but PFBA was not among those measured. PFBA has also been detected in breastmilk and baby food products, indicating a potential additional route of exposure for infants. Antignac et al. (2013) reports that PFBA was detected in 17% (8 of 48) of breastmilk samples in a population of French mothers, with a mean concentration of 0.081 μg/L. Lorenzo et al. (2016) further reported that PFBA was detected in breastmilk, infant formulas, dry cereal baby food, and processed baby food in Valencia, Spain.

Although PFBA-specific exposure information is sparse, populations that might experience exposures greater than those of the general population could include individuals in occupations that require frequent contact with materials containing PFAS that break down into PFBA, such as individuals working with stain-resistant fabrics, paper food packaging, ski wax, and carpets (see Section 1.1.2). For example, Nilsson et al. (2010) observed a significant correlation between the number of years individuals had worked as ski wax technicians and their blood levels of PFBA. Populations living near fluorochemical facilities where environmental contamination to PFAS that can break down into PFBA has occurred might also be more highly exposed.

## 1.2 SUMMARY OF ASSESSMENT METHODS

Section 1.2 summarizes the methods used for developing this assessment. A more detailed description of the methods for each step of the assessment development process is provided in the systematic review protocol (see Appendix A). The protocol includes additional problem formulation details, including the specific aims and key science issues identified for this assessment.

### 1.2.1 Literature Search and Screening

The detailed search approach, including the query strings and Populations, Exposures, Comparators, and Outcomes (PECO) criteria (see Table 1-3), are provided in Appendix A, Section 4, and Appendix B, respectively. The results of the current literature search and screening efforts are documented below. Briefly, a literature search was first conducted in 2017 and regular updates are performed (the literature searches will continue to be updated until shortly before release of the document for public comment). The literature search queries the following databases (no date or language restrictions were applied):

- PubMed (National Library of Medicine (https://www.ncbi.nlm.nih.gov/pubmed/))
- Web of Science (Thomson Reuters (https://apps.webofknowledge.com/))
- Toxline (National Library of Medicine (https://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?TOXLINE))^7^
- TSCATS (Toxic Substances Control Act Test Submissions (https://cfpub.epa.gov/si/si_public_record_Report.cfm?dirEntryId=2855))

In addition, relevant literature not found through database searching was identified by:

- Review of studies cited in any PFBA PECO-relevant studies and published journal reviews; finalized or draft U.S. state, U.S. federal, and international assessments (e.g., the draft Agency for Toxic Substances and Disease Registry [ATSDR] assessment released publicly in 2018). In addition, studies included in ongoing IRIS PFAS assessments (PFHxA, PFHxS, PFNA, PFDA) were also scanned for any studies that met PFBA PECO criteria.
- Review of studies submitted to federal regulatory agencies and brought to the attention of EPA. For example, studies submitted to EPA by the manufacturers in support of requirements under the Toxic Substances Control Act (TSCA).
- Identification of studies during screening for other PFAS. For example, epidemiological studies relevant to PFBA sometimes were identified by searches focused on one of the other four PFAS currently being assessed by the Integrated Risk Information System (IRIS) Program.
- Other gray literature (e.g., primary studies not indexed in typical databases, such as technical reports from government agencies or scientific research groups; unpublished laboratory studies conducted by industry; or working reports/white papers from research groups or committees) brought to the attention of EPA.

All literature is tracked in the U.S. EPA Health and Environmental Research Online (HERO) database (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2632). The PECO criteria (see Table 1-3) identify the evidence that addresses the specific aims of the assessment and to focus the literature screening, including study inclusion/exclusion.

Table 1-3 Populations, Exposures, Comparators, and Outcomes (PECO) criteria

PECO element | Evidence
[underlined: P]opulations | Human: Any population and lifestage (occupational or general population, including children and other sensitive populations). The following study designs will be included: controlled exposure, cohort, case control, and cross-sectional. (Note: Case reports and case series will be tracked as potential supplemental material.); Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).; Other: In vitro, in silico, or nonmammalian models of genotoxicity. (Note: Other in vitro, in silico, or nonmammalian models will be tracked as potential supplemental material.)
[underlined: E]xposures | Human: Studies providing quantitative estimates of PFBA exposure based on administered dose or concentration, biomonitoring data (e.g., urine, blood, or other specimens), environmental or occupational-setting measures (e.g., water levels or air concentrations, residential location or duration, job title, or work title). (Note: Studies that provide qualitative, but not quantitative, estimates of exposure will be tracked as supplemental material.); Animal: Oral or inhalation studies including quantified exposure to PFBA based on administered dose, dietary level, or concentration. (Note: Nonoral and noninhalation studies will be tracked as potential supplemental material.) PFBA mixture studies are included if they employ an experimental arm that involves exposure to PFBA alone. (Note: Other PFBA mixture studies will be tracked as potential supplemental material.); Studies must address exposure to the following: PFBA (CASRN 375-22-4), or the ammonium salt NH4^+^PFB (CASRN 10495-86-0). [Note: Although PFBAs are not metabolized or transformed in the body, precursor compounds known to be bio-transformed to a PFAS are of interest, e.g., 6:2 fluorotelomer alcohol is metabolized to multiple analytes including PFHxA and PFBA (Russell et al., 2015b). Thus, studies of precursor PFAS that identify and quantify PFBA will be tracked as potential supplemental material (e.g., for ADME analyses or interpretations).]
[underlined: C]omparators | Human: A comparison or reference population exposed to lower levels (or no exposure/exposure below detection levels) or for shorter periods of time.; Animal: Includes comparisons to historical controls or a concurrent control group that is unexposed, exposed to vehicle-only or air-only exposures. (Note: Experiments including exposure to PFBA across different durations or exposure levels without including one of these control groups will be tracked as potential supplemental material [e.g., for evaluating key science issues; see Appendix A, Section 2.4 of the protocol].)
[underlined: O]utcomes | All cancer and noncancer health outcomes. (Note: Other than genotoxicity studies, studies including only molecular endpoints [e.g., gene or protein changes; receptor binding or activation] or other nonphenotypic endpoints addressing the potential biological or chemical progression of events contributing toward toxic effects will be tracked as potential supplemental material [e.g., for evaluating key science issues; see Appendix A, Section 2.4 of the protocol].)

In addition to those studies meeting the PECO criteria and studies excluded as not relevant to the assessment, studies containing supplemental material potentially relevant to the specific aims of the assessment were inventoried during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues (see Appendix A, Section 2.4) and other potential scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material” included the following:

- In vivo mechanistic or mode of action studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and populations (e.g., nonmammalian models)
- In vitro and in silico models
- Absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic studies (excluding models)^8^
- Exposure assessment or characterization (no health outcome) studies
- Human case reports or case series studies

The literature was screened by two independent reviewers with a process for conflict resolution, first at the title and abstract level and subsequently the full-text level, using structured forms in DistillerSR (Evidence Partners; https://distillercer.com/products/distillersr-systematic-review-software/). Literature inventories for PECO-relevant studies and studies tagged as “potentially relevant supplemental material” during screening were created to facilitate subsequent review of individual studies or sets of studies by topic-specific experts.

### 1.2.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiological and animal toxicological studies used in the PFBA assessment are provided in the systematic review protocol (see Appendix A, Section 6). The general approach for evaluating PECO-relevant health effect studies is the same for epidemiological and animal toxicological studies, although the specifics of applying the approach differ; thus, they are described in detail in Appendices A, Sections 6.2 and 6.3, respectively. Approaches for evaluating mechanistic evidence are described in detail in Appendix A, Section 6.5.

The key concerns for the review of epidemiological and animal toxicological studies are potential bias (systematic errors or deviations from the truth related to internal validity that affect the magnitude or direction of an effect in either direction), and insensitivity (factors that limit the ability of a study to detect a true effect; low sensitivity is a bias toward the null when an effect exists). In evaluating individual studies, two or more reviewers independently arrived at judgments regarding the reliability of the study results (reflected as study confidence determinations; see below) with regard to each outcome or outcome grouping of interest; thus, different judgments were possible for different outcomes within the same study. The results of these reviews were tracked within EPA’s version of the Health Assessment Workplace Collaboration (HAWC (https://hawcprd.epa.gov/assessment/100500073/)). To develop these judgments, each reviewer assigned a category of good, adequate, deficient (or not reported, which generally carried the same functional interpretation as deficient), or critically deficient (listed from best to worst methodological conduct; see Appendix A, Section 6 for definitions) related to each evaluation domain representing the different characteristics of the study methods that were evaluated on the basis of the criteria outlined in HAWC.

Once all evaluation domains were evaluated, the identified strengths and limitations were collectively considered by the reviewers to reach a final study confidence classification:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely to be of a notable degree or to have a notable impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight than high or medium confidence results during evidence synthesis and integration (see Sections 1.2.4 and 1.2.5).
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Using the HAWC platform (and conflict resolution by an additional reviewer, as needed), the reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination. The specific limitations identified during study evaluation were carried forward to inform the synthesis (see Section 1.2.4) within each body of evidence for a given health effect (i.e., study confidence determinations were not used to inform judgments in isolation).

### 1.2.3 Data Extraction

The detailed data extraction approach is provided in Appendix A, Section 8. Briefly, data extraction and content management were carried out using HAWC. Data extraction elements that were collected from epidemiological, controlled human exposure, animal toxicological, and in vitro studies are described in HAWC (https://hawcprd.epa.gov/about/). Not all studies that meet the PECO criteria went through data extraction: studies evaluated as being uninformative were not considered further and therefore did not undergo data extraction, and outcomes determined to be less relevant during PECO refinement did not go through data extraction. The same was true for low confidence studies when medium and high confidence studies (e.g., on an outcome) were available. All findings are considered for extraction, regardless of the statistical significance of their findings. The level of extraction for specific outcomes within a study could differ (i.e., ranging from a narrative to full extraction of dose-response effect size information). For quality control, data extraction was performed by one member of the evaluation team and independently verified by at least one other member. Discrepancies in data extraction were resolved by discussion or consultation within the evaluation team.

### 1.2.4 Evidence Synthesis and Integration

For the purposes of this assessment, evidence synthesis and integration are considered distinct but related processes (see Appendix A, Sections 9 and 10 for full details). For each assessed health effect, the evidence syntheses provide a summary discussion of each body of evidence considered in the review that directly informs the integration across evidence to draw an overall judgment for each health effect. The available human and animal evidence pertaining to the potential health effects are synthesized separately, with each synthesis providing a summary discussion of the available evidence that addresses considerations regarding causation that are adapted from (Hill, 1965). Mechanistic evidence is also synthesized as necessary to help inform key decisions regarding the human and animal evidence; processes for synthesizing mechanistic information are covered in detail in Appendix A, Section 9.2.

The syntheses of the human and animal health effects evidence focus on describing aspects of the evidence that best inform causal interpretations, including the exposure context examined in the sets of studies. The evidence synthesis is based primarily on studies of high and medium confidence. Low confidence studies could be used if few or no studies with higher confidence are available to help evaluate consistency, or if the study designs of the low confidence studies address notable uncertainties in the set of high or medium confidence studies on a given health effect. If low confidence studies are used, a careful examination of the study evaluation and sensitivity with potential effects on the evidence synthesis conclusions will be included in the narrative. When possible, results across studies are compared using graphs and charts or other data visualization strategies. The synthesis of mechanistic information informs the integration of health effects evidence for both hazard identification (e.g., biological plausibility or coherence of the available human or animal evidence; inferences regarding human relevance, or the identification of susceptible populations and lifestages across the human and animal evidence) and dose-response evaluation (e.g., selection of benchmark response levels, selection of uncertainty factors). Evaluations of mechanistic information typically differ from evaluations of phenotypic evidence (e.g., from routine toxicological studies). This is primarily because mechanistic data evaluations consider the support for and involvement of specific events or sets of events within the context of a broader research question (e.g., support for a hypothesized mode of action; consistency with known biological processes), rather than evaluations of individual apical endpoints considered in relative isolation.

Following the synthesis of human and animal health effects data, and mechanistic data, integrated judgments are drawn across all lines of evidence for each assessed health effect. During evidence integration, a structured and documented two-step process is used, as follows:

Building from the separate syntheses of the human and animal evidence, the strength of the evidence from the available human and animal health effect studies are summarized in parallel, but separately, using a structured evaluation of an adapted set of considerations first introduced by Sir Bradford Hill (Hill, 1965). This process is similar to that used by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) (Morgan et al., 2016; Guyatt et al., 2011; Schünemann et al., 2011), which arrives at an overall integration conclusion based on consideration of the body of evidence. These summaries incorporate the relevant mechanistic evidence (or mode-of-action [MOA] understanding) that informs the biological plausibility and coherence within the available human or animal health effect studies. The terms associated with the different strength of evidence judgments within evidence streams are robust, moderate, slight, indeterminate, and compelling evidence of no effect.

The animal, human, and mechanistic evidence judgments are then combined to draw an overall judgment that incorporates inferences across evidence streams. Specifically, the inferences considered during this integration include the human relevance of the animal and mechanistic evidence, coherence across the separate bodies of evidence, and other important information (e.g., judgments regarding susceptibility). Note that without evidence to the contrary, the human relevance of animal findings is assumed. The final output is a summary judgment of the evidence base for each potential human health effect across evidence streams. The terms associated with these summary judgments are evidence demonstrates, evidence indicates (likely), evidence suggests, evidence inadequate, and strong evidence of no effect. The decision points within the structured evidence integration process are summarized in an evidence profile table for each considered health effect.

As discussed in the protocol (see Appendix A), the methods for evaluating the potential carcinogenicity of PFAS follow processes laid out in the EPA cancer guidelines U.S. EPA (2005) and that the judgements described here for different cancer types are used to inform the evidence integration narrative for carcinogenicity and selection of one of EPA’s standardized cancer descriptions. These are: (1) carcinogenic to humans, (2) likely to be carcinogenic to humans, (3) suggestive evidence of carcinogenic potential, (4) inadequate information to assess carcinogenic potential, or (5) not likely to be carcinogenic to humans. However, for PFBA, data relevant to cancer were sparse and did not allow for such an evaluation (see Section 3.3).

### 1.2.5 Dose-Response Analysis

The details for the dose-response employed in this assessment can be found in Appendix A, Section 11. Briefly, a dose-response assessment was performed for noncancer health hazards, following exposure to PFBA via the oral route, as supported by existing data. For oral noncancer hazards, oral reference doses (RfDs) are derived when possible. An RfD is an estimate, with uncertainty spanning perhaps an order of magnitude, of an exposure to the human population (including susceptible subgroups) that is likely to be without an appreciable risk of deleterious health effects over a lifetime (U.S. EPA, 2002). The derivation of a reference value like the RfD depends on the nature of the health hazard conclusions drawn during evidence integration. For noncancer outcomes, a dose-response assessment was conducted for evidence integration conclusions of evidence demonstrates or evidence indicates (likely). In general, toxicity values are not developed for noncancer hazards with evidence suggests conclusions (see Appendix A, Section 10.2 for exceptions).

Consistent with EPA practice, the PFBA assessment applied a two-step approach for dose-response assessment that distinguishes analysis of the dose-response data in the range of observation from any inferences about responses at lower environmentally relevant exposure levels (U.S. EPA, 2012, 2005):

- Within the observed dose range, the preferred approach was to use dose-response modeling to incorporate as much of the data set as possible into the analysis. This modeling to derive a point of departure (POD) ideally includes an exposure level near the lower end of the range of observation, without significant extrapolation to lower exposure levels.
- As derivation of cancer risk estimates and reference values nearly always involves extrapolation to exposures lower than the POD; the approaches to be applied in these assessments are described in more detail in Appendix A, Section 11.2.

When sufficient and appropriate human and laboratory animal data are available for the same outcome, human data are generally preferred for the dose-response assessment because use of human data eliminates the need to perform interspecies extrapolations. For reference values, this assessment will derive a candidate value from each suitable data set. Evaluation of these candidate values will yield a single organ/system-specific value for each organ/system under consideration from which a single overall reference value will be selected to cover all health outcomes across all organs/systems. Although this overall reference value represents the focus of these dose-response assessments, the organ/system-specific values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple PFAS (or other agents) acting at a common organ/system. For noncancer toxicity values, uncertainties in these estimates are characterized and discussed.

For dose-response purposes, EPA has developed a standard set of models (http://www.epa.gov/bmds) that can be applied to typical data sets, including those that are nonlinear. In situations where alternative models with significant biological support are available (e.g., pharmacodynamic models), those models are included as alternatives in the assessment(s) along with a discussion of the models’ strengths and uncertainties. EPA has developed guidance on modeling dose-response data, assessing model fit, selecting suitable models, and reporting modeling results [see the EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012)]. Additional judgment or alternative analyses are used if the procedure fails to yield reliable results; for example, if the fit is poor, modeling might be restricted to the lower doses, especially if competing toxicity at higher doses occurs. When alternative approaches fail or are not applicable, the NOAEL/LOAEL approach is used for POD estimation. For each modeled response, a POD from the observed data was estimated to mark the beginning of extrapolation to lower doses. The POD is an estimated dose (expressed in human-equivalent terms) near the lower end of the observed range without significant extrapolation to lower doses. The POD is used as the starting point for subsequent extrapolations and analyses. For noncancer effects, the POD is used in calculating the RfD.

6 As part of the National Defense Authorization Act for Fiscal Year 2020 (Section 7321), 172 per- and polyfluoroalkyl substances will be added to the TRI list; however, neither PFBA nor its ammonium salt is on the list of PFAS subject to TRI reporting requirements for Reporting Year 2022.

7 Toxline has recently been moved into PubMed as part of a broad National Library of Medicine reorganization. Toxline searches can now be conducted within PubMed.

8 Given the known importance of ADME data, this supplemental tagging was used as the starting point for a separate screening and review of toxicokinetics data (see Appendix A, Section 9.2 for details).