# ABBREVIATIONS AND ACRONYMS

ACO: acyl-CoA oxidase
ADME: absorption, distribution, metabolism, and excretion
AFFF: aqueous film-forming foam
AIC: Akaike’s information criterion
ALP: alkaline phosphatase
ALT: alanine aminotransferase
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: area-under-the-concentration curve
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BW: body weight
C_AVG_: average concentration
C_MAX_: maximum concentration
CA: Cochran-Armitage
CAR: constitutive androstane receptor
CASRN: Chemical Abstracts Service registry number
CDR: Chemical Data Reporting
CI: confidence interval
CL: clearance
CL_A_: clearance in animals
CL_H_: clearance in humans
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CV: constant variance
CYP: cytochrome P450 superfamily
DAF: dosimetric adjustment factor
DNA: deoxyribonucleic acid
DNT: developmental neurotoxicity
DOD: Department of Defense
EPA: Environmental Protection Agency
EOP: Executive Office of the President
ER: extra risk
FLR: full-litter resorption
FTOH: fluorotelomer alcohol
GD: gestation day
GFR: glomerular filtration rate
GGT: γ-glutamyl transferase
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
GSH: glutathione
HAWC: Health Assessment Workspace Collaborative
HED: human equivalent dose
HERO: Health and Environmental Research Online
HISA: highly influential scientific information
HPT: hypothalamic-pituitary-thyroid
IRIS: Integrated Risk Information System
i.v.: intravenous
IQ: intelligence quotient
IQR: interquartile range
ISI: influential scientific information
IUR: inhalation unit risk
LLOQ: lower limit of quantitation
LN: log-normal
LOAEL: lowest-observed-adverse-effect level
MBq: megabecquerel
MOA: mode of action
NCEA: National Center for Environmental Assessment
NCV: nonconstant variance
NIOSH: National Institute for Occupational Safety and Health
NIS: sodium-iodide symporter
NOAEL: no-observed-adverse-effect level
NPL: National Priority List
NTP: National Toxicology Program
OAT: organic anion transporter
OECD: Organisation for Economic Co-operation and Development
OMB: Office of Management and Budget
ORD: Office of Research and Development
OSF: oral slope factor
PC: partition coefficient
PBPK: physiologically based pharmacokinetic
PBTK: physiologically based toxicokinetic
PD: pharmacodynamic
PECO: Populations, Exposures, Comparators, Outcomes
PFAA: perfluoroalkyl acid
PFAS: per- and polyfluoroalkyl substances
PFBA: perfluorobutanoic acid
PFBS: perfluorobutane sulfonate
PFCA: perfluoroalkyl carboxylic acid
PFDA: perfluorodecanoic acid
PFHxA: perfluorohexanoic acid
PFHxS: perfluorohexane sulfonate
PFNA: perfluorononanoic acid
PFOA: perfluorooctanoic acid
PFOS: perfluorooctane sulfonate
PK: pharmacokinetic
PND: postnatal day
POD: point of departure
POD_HED_: human equivalent dose POD
PPAR: peroxisome proliferator-activated receptor
PQAPP: Programmatic Quality Assurance Project Plan
PT: prothrombin time
PXR: pregnane X receptor
QA: quality assurance
QAPP: Quality Assurance Project Plan
QMP: Quality Management Plan
RBC: red blood cell
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
RS: Rao-Scott
SD: standard deviation
S-D: Sprague-Dawley
SE: standard error
TD: toxicodynamic
TH: thyroid hormone
TK: toxicokinetic
TPO: thyroid peroxidase
TRI: Toxic Release Inventory
TSCA: Toxic Substances Control Act
TSCATS: Toxic Substances Control Act Test Submissions
TSH: thyroid-stimulating hormone
TSHR: thyroid-stimulating hormone receptor
UCMR: Unregulated Contaminant Monitoring Rule
UDP-GT: uridine 5′-diphospho-glucuronosyltransferase
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
V _d_: volume of distribution
VOC: volatile organic compound
WOS: Web of Science
Wy-14,643: pirinixic acid