# REFERENCES

Acharya, S; Mehta, K; Rodrigues, S; Pereira, J; Krishnan, S; Rao, CV. (1995). Administration of subtoxic doses of t-butyl alcohol and trichloroacetic acid to male Wistar rats to study the interactive toxicity. Toxicology Letters 80: 97–104. 10.1016/0378-4274(95)03340-Q 7482597
Acharya, S; Mehta, K; Rodriguez, S; Pereira, J; Krishnan, S; Rao, CV. (1997). A histopathological study of liver and kidney in male Wistar rats treated with subtoxic doses of t-butyl alcohol and trichloroacetic acid. Experimental and Toxicologic Pathology 49: 369–373. 10.1016/S0940-2993(97)80119-4 9455684
Amberg, A; Rosner, E; Dekant, W. (1999). Biotransformation and kinetics of excretion of methyl-tert-butyl ether in rats and humans. Toxicological Sciences 51: 1–8.10496672
Amberg, A; Rosner, E; Dekant, W. (2000). Biotransformation and kinetics of excretion of ethyl tert-butyl ether in rats and humans. Toxicological Sciences 53: 194–201. 10.1093/toxsci/53.2.194 10696767
ARCO (ARCO Chemical Company). (1983). Toxicologist’s report on metabolism and pharmacokinetics of radiolabeled TBA 534 tertiary butyl alcohol with cover letter dated 03/24/1994. (8EHQ86940000263). Newton Square, PA.
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Toxicological profile for methyl-tert-butyl ether [ATSDR Tox Profile]. Atlanta, GA; U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp91.pdf
Bailer, AJ; Portier, CJ. (1988). Effects of treatment-induced mortality and tumor-induced mortality on tests for carcinogenicity in small samples. Biometrics 44: 417–431. 10.2307/2531856 3390507
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicologic Pathology 32: 448–466. 10.1080/01926230490465874 15204968
Bale, AS; Lee, JS. (2016). An overview of butanol-induced developmental neurotoxicity and the potential mechanisms related to these observed effects [Review]. Neurotoxicology and Teratology 53: 33–40. 10.1016/j.ntt.2015.11.006 26582497
Banton, MI; Peachee, VL; White, KL; Padgett, EL. (2011). Oral subchronic immunotoxicity study of ethyl tertiary butyl ether in the rat. Journal of Immunotoxicology 8: 298–304. 10.3109/1547691X.2011.598480 21827378
Bernauer, U; Amberg, A; Scheutzow, D; Dekant, W. (1998). Biotransformation of 12C- and 2-13C-labeled methyl tert-butyl ether, ethyl tert-butyl ether, and tert-butyl alcohol in rats: Identification of metabolites in urine by 13C nuclear magnetic resonance and gas chromatography/mass spectrometry. Chemical Research in Toxicology 11: 651–658. 10.1021/tx970215v 9625733
Blanck, O; Fowles, J; Schorsch, F; Pallen, C; Espinasse-Lormeau, H; Schulte-Koerne, E, (2010). Tertiary butyl alcohol in drinking water induces phase I and II liver enzymes with consequent effects on thyroid hormone homeostasis in the B6C3F1 female mouse. Journal of Applied Toxicology 30: 125–132. 10.1002/jat.1478 19760798
Borghoff, SJ; Murphy, JE; Medinsky, MA. (1996). Development of a physiologically based pharmacokinetic model for methyl tertiary-butyl ether and tertiary-butanol in male Fischer-344 rats. Toxicological Sciences 30: 264–275. 10.1006/faat.1996.0064
Borghoff, SJ; Prescott, JS; Janszen, DB; Wong, BA; Everitt, JI. (2001). alpha2u-Globulin nephropathy, renal cell proliferation, and dosimetry of inhaled tert-butyl alcohol in male and female F-344 rats. Toxicological Sciences 61: 176–186. 10.1093/toxsci/61.1.176 11294988
Borghoff, SJ; Ring, C; Banton, MI; Leavens, TL. (2016). Physiologically based pharmacokinetic model for ethyl tertiary-butyl ether and tertiary-butyl alcohol in rats: Contribution of binding to α2u-globulin in male rats and high-exposure nonlinear kinetics to toxicity and cancer outcomes. Journal of Applied Toxicology 37: 621–640. 10.1002/jat.3412 27885692
CalEPA (California Environmental Protection Agency). (1999). Expedited evaluation of risk assessment for tertiary butyl alcohol in drinking water. Available online at http://www.oehha.ca.gov/water/pals/tba.html
Capen, CC; Dybing, E; Rice, JM; Wilbourn, JD. (1999). Species differences in thyroid, kidney and urinary bladder carcinogenesis. In CC Capen; E Dybing; JM Rice: JD Wilbourn (Eds.), (pp. 1–225). Lyon, France: International Agency for Research on Cancer.
Cederbaum, AI; Cohen, G. (1980). Oxidative demethylation of t-butyl alcohol by rat liver microsomes. Biochemical and Biophysical Research Communications 97: 730–736. 10.1016/0006-291X(80)90325-3 7470124
Cederbaum, AI; Qureshi, A; Cohen, G. (1983). Production of formaldehyde and acetone by hydroxyl-radical generating systems during the metabolism of tertiary butyl alcohol. Biochemical Pharmacology 32: 3517–3524. 10.1016/0006-2952(83)90297-6 6316986
Chen, M. (2005). Amended final report of the safety assessment of t-butyl alcohol as used in cosmetics [Review]. International Journal of Toxicology 24 Suppl 2: 1–20. 10.1080/10915810590953833
Cirvello, JD; Radovsky, A; Heath, JE; Farnell, DR; Lindamood III, C. (1995). Toxicity and carcinogenicity of t-butyl alcohol in rats and mice following chronic exposure in drinking water. Toxicology and Industrial Health 11: 151–165. 10.1177/074823379501100203 7491631
Craig, EA; Yan, Z; Zhao, QJ. (2015). The relationship between chemical-induced kidney weight increases and kidney histopathology in rats. Journal of Applied Toxicology 35: 729–736. 10.1002/jat.3036 25092041
Daniel, MA; Evans, MA. (1982). Quantitative comparison of maternal ethanol and maternal tertiary butanal diet on postnatal development. Journal of Pharmacology and Experimental Therapeutics 222: 294–300.7097549
Dickey, FH; Cleland, GH; Lotz, C. (1949). The role of organic peroxides in the induction of mutations. Proceedings of the National Academy of Sciences 35: 581–586.
Faulkner, TP; Wiechart, JD; Hartman, DM; Hussain, AS. (1989). The effects of prenatal tertiary butanol administration in CBA/J and C57BL/6J mice. Life Sciences 45: 1989–1995.2601562
FDA (U.S. Food and Drug Administration). (2015a). Indirect food additives: Adjuvants, production aids, and sanitizers. Surface lubricants used in the manufacture of metallic articles. 21 CFR 178.3910 (pp. 1–7). http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?fr=178.3910
FDA (U.S. Food and Drug Administration). (2015b). Indirect food additives: Paper and paperboard components. Defoaming agents used in coatings. 21 CFR 176.200 (pp. 1–4). http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?fr=176.200
Frazier, KS; Seely, JC; Hard, GC; Betton, G; Burnett, R; Nakatsuji, S, (2012). Proliferative and nonproliferative lesions of the rat and mouse urinary system. Toxicologic Pathology 40: 14S–86S. 10.1177/0192623312438736 22637735
Gaoua, W. (2004a). Ethyl tertiary butyl ether (ETBE): Prenatal developmental toxicity study by the oral route (gavage) in rats (pp. 1–280). (CIT Study No. 24860 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Gaoua, W. (2004b). Ethyl tertiary butyl ether (ETBE): Two-generation study (reproduction and fertility effects) by the oral route (gavage) in rats. (CIT Study No. 24859 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Gehlhaus, MW, III; Gift, JS; Hogan, KA; Kopylev, L; Schlosser, PM; Kadry, AR. (2011). Approaches to cancer assessment in EPA’s Integrated Risk Information System [Review]. Toxicology and Applied Pharmacology 254: 170–180. 10.1016/j.taap.2010.10.019 21034767
Gorriz, JL; Martinez-Castelao, A. (2012). Proteinuria: Detection and role in native renal disease progression. Transplantation Reviews 26: 3–13. 10.1016/j.trre.2011.10.002 22137726
Hard, GC. (1986). Experimental models for the sequential analysis of chemically-induced renal carcinogenesis. Toxicologic Pathology 14: 112–122. 10.1177/019262338601400114 3012758
Hard, GC. (2008). Some aids to histological recognition of hyaline droplet nephropathy in ninety-day toxicity studies. Toxicologic Pathology 36: 1014–1017. 10.1177/0192623308327413 19126795
Hard, GC; Banton, MI; Bretzlaff, RS; Dekant, W; Fowles, JR; Mallett, AK, (2013). Consideration of rat chronic progressive nephropathy in regulatory evaluations for carcinogenicity. Toxicological Sciences 132: 268–275. 10.1093/toxsci/kfs305 23104430
Hard, GC; Bruner, RH; Cohen, SM; Pletcher, JM; Regan, KS. (2011). Renal histopathology in toxicity and carcinogenicity studies with tert-butyl alcohol administered in drinking water to F344 rats: A pathology working group review and re-evaluation. Regulatory Toxicology and Pharmacology 59: 430–436. 10.1016/j.yrtph.2011.01.007 21296119
Hard, GC; Cohen, SM; Ma, J; Yu, F; Arnold, LL; Banton, MI. (2019). Histopathology re-examination of the NTP toxicity/carcinogenicity studies of tert-butyl alcohol to identify renal tumor and toxicity modes of action. Regulatory Toxicology and Pharmacology 102: 65–73. 10.1016/j.yrtph.2018.12.011 30590081
Hard, GC; Johnson, KJ; Cohen, SM. (2009). A comparison of rat chronic progressive nephropathy with human renal disease-implications for human risk assessment [Review]. Critical Reviews in Toxicology 39: 332–346. 10.1080/10408440802368642 19514917
Hard, GC; Khan, KN. (2004). Invited review: A contemporary overview of chronic progressive nephropathy in the laboratory rat, and its significance for human risk assessment [Review]. Toxicologic Pathology 32: 171–180. 10.1080/01926230490422574 15200155
Hard, GC; Seely, JC. (2005). Recommendations for the interpretation of renal tubule proliferative lesions occurring in rat kidneys with advanced chronic progressive nephropathy (CPN). Toxicologic Pathology 33: 641–649. 10.1080/01926230500299716 16207638
Hard, GC; Seely, JC. (2006). Histological investigation of diagnostically challenging tubule profiles in advanced chronic progressive nephropathy (CPN) in the Fischer 344 RaT. Toxicologic Pathology 34: 941–948. 10.1080/01926230601083381 17178694
Hard, GC; Wolf, DC. (1999). Re-evaluation of the chloroform 2-year drinking water bioassy in Osborne-Mendel rats indicates that sustained renal tubule injury is associated with renal tumor development [Abstract]. Toxicologist 48: 30.
HSDB (Hazardous Substances Data Bank). (2007). t-Butyl alcohol [Database]. Bethesda, MD: National Library of Medicine. Retrieved from https://pubchem.ncbi.nlm.nih.gov/compound/6386
Huntingdon Life Sciences. (2004). Reproductive and developmental toxicity screening test in rats by oral gavage. (Study No. 03-4254). East Millstone, NJ; Lyondell Chemical Company.
Hurley, PM. (1998). Mode of carcinogenic action of pesticides inducing thyroid follicular cell tumors in rodents. Environmental Health Perspectives 106: 437–445. 10.1289/ehp.98106437 9681970
IARC (International Agency for Research on Cancer). (1999). Methyl tert-butyl ether (group 3). In Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances (pp. 339–383). Lyon, France.
IPCS (International Programme on Chemical Safety). (1987). Butanols: Four isomers: 1-butanol, 2-butanol, tert-butanol, isobutanol [WHO EHC]. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc65.htm
Kaneko, T; Wang, PY; Sato, A. (2000). Partition coefficients for gasoline additives and their metabolites. Journal of Occupational Health 42: 86–87. 10.1539/joh.42.86
Leavens, TL; Borghoff, SJ. (2009). Physiologically based pharmacokinetic model of methyl tertiary butyl ether and tertiary butyl alcohol dosimetry in male rats based on binding to alpha2u-globulin. Toxicological Sciences 109: 321–335. 10.1093/toxsci/kfp049 19270017
Lee, JS; Ward, WO; Liu, J; Ren, H; Vallanat, B; Delker, D, (2011). Hepatic xenobiotic metabolizing enzyme and transporter gene expression through the life stages of the mouse. PLoS ONE 6: e24381. 10.1371/journal.pone.0024381 21931700
Lee, JS; Ward, WO; Wolf, DC; Allen, JW; Mills, C; Devito, MJ, (2008). Coordinated changes in xenobiotic metabolizing enzyme gene expression in aging male rats. Toxicological Sciences 106: 263–283. 10.1093/toxsci/kfn144 18653662
Li, Q; Kobayashi, M; Inagaki, H; Hirata, Y; Hirata, K; Shimizu, T, (2011). Effects of subchronic inhalation exposure to ethyl tertiary butyl ether on splenocytes in mice. International Journal of Immunopathology and Pharmacology 24: 837–847. 10.1177/039463201102400403 22230391
Lindamood, C, III; Farnell, DR; Giles, HD; Preiean, JD; Collins, JJ; Takahashi, K, (1992). Subchronic toxicity studies of t-butyl alcohol in rats and mice. Fundamental and Applied Toxicology 19: 91–100. 10.1093/toxsci/19.1.91 1397807
Lusco, MA; Fogo, AB; Najafian, B; Alpers, CE. (2016). AJKD Atlas of Renal Pathology: Tubular Atrophy. American Journal of Kidney Diseases 67: e33–e34. 10.1053/j.ajkd.2016.04.007 27211375
Maronpot, RR; Yoshizawa, K; Nyska, A; Harada, T; Flake, G; Mueller, G, (2010). Hepatic enzyme induction: Histopathology [Review]. Toxicologic Pathology 38: 776–795. 10.1177/0192623310373778 20585142
McGregor, D. (2010). Tertiary-butanol: A toxicological review [Review]. Critical Reviews in Toxicology 40: 697–727. 10.3109/10408444.2010.494249 20722584
Mcgregor, DB; Brown, A; Cattanach, P; Edwards, I; Mcbride, D; Caspary, WJ. (1988). Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environmental and Molecular Mutagenesis 11: 91–118. 10.1002/em.2850110110 3338442
McGregor, DB; Cruzan, G; Callander, RD; May, K; Banton, M. (2005). The mutagenicity testing of tertiary-butyl alcohol, tertiary-butyl acetate and methyl tertiary-butyl ether in Salmonella typhimurium. Mutation Research 565: 181–189. 10.1016/j.mrgentox.2004.10.002 15661616
Melnick, R; Burns, K; Ward, J; Huff, J. (2012). Chemically exacerbated chronic progressive nephropathy not associated with renal tubule tumor induction in rats: An evaluation based on 60 carcinogenicity studies by the National Toxicology Program. Toxicological Sciences 128: 346–356. 10.1093/toxsci/kfs156 22539614
Melnick, RL; Ward, JM; Huff, J. (2013). War on carcinogens: Industry disputes human relevance of chemicals causing cancer in laboratory animals based on unproven hypotheses, using kidney tumors as an example [Editorial]. International Journal of Occupational and Environmental Health 19: 255–260. 10.1179/1077352513Z.00000000090 24588032
Nelson, BK; Brightwell, WS; Khan, A; Burg, JR; Goad, PT. (1989). Lack of selective developmental toxicity of three butanol isomers administered by inhalation to rats. Fundamental and Applied Toxicology 12: 469–479. 10.1093/toxsci/12.3.469 2731662
Nelson, BK; Brightwell, WS; Khan, A; Shaw, PB; Krieg, EF, Jr; Massari, VJ. (1991). Behavioral teratology investigation of tertiary-butanol administered by inhalation to rats. Pharmacopsychoecologia 4: 1–7.
NIEHS (National Institute of Environmental Health Sciences). (2019). NTP pathology consult for ETBE and tBA. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
Nihlén, A; Löf, A; Johanson, G. (1995). Liquid/air partition coefficients of methyl and ethyl t-butyl ethers, t-amyl methyl ether, and t-butyl alcohol. Journal of Exposure Analysis and Environmental Epidemiology 5: 573–582.8938250
Nihlén, A; Löf, A; Johanson, G. (1998a). Controlled ethyl tert-butyl ether (ETBE) exposure of male volunteers: I Toxicokenetics. Toxicological Sciences 46: 1–10. 10.1006/toxs.1998.2516 9928663
Nihlén, A; Löf, A; Johanson, G. (1998b). Experimental exposure to methyl tertiary-butyl ether: I Toxicokinetics in humans. Toxicology and Applied Pharmacology 148: 274–280. 10.1006/taap.1997.8333 9473535
NIOSH (National Institute for Occupational Safety and Health). (2005). NIOSH pocket guide to chemical hazards: tert-butyl alcohol. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgd0078.html
NIOSH (National Institute for Occupational Safety and Health). (2007). NIOSH pocket guide to chemical hazards. (DHHS Publication No. (NIOSH) 2005-149; CBRNIAC-CB-112149). Cincinnati, OH; Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/docs/2005-149/
NRC (National Research Council). (2011). Review of the Environmental Protection Agency’s draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142
NSF International. (2003). t-Butanol: Oral Risk Assessment Document (CAS 75-65-0) (pp. 81). Ann Arbor, MI.
NTP (National Toxicology Program). (1995). Toxicology and carcinogenesis studies of t-butyl alcohol (CAS no 75-65-0) in F344/N rats and B6C3F1 mice (Drinking water studies). (NTPTR436). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. https://ntp.niehs.nih.gov/ntp/htdocs/ltrpts/tr436.pdf
NTP (National Toxicology Program). (1997). NTP technical report on toxicity studies of t-butyl alcohol (CAS no 75-65-0) administered by inhalation to F344/N rats and B6C3F1 mice. (NIH Pub 97-3942). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. http://ntp.niehs.nih.gov/ntp/htdocs/STrpts/tox053.pdf
NTP (National Toxicology Program). (2015). Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. Research Triangle Park, NC: U.S. Deptartment of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015508.pdf
OSHA (Occupational Safety & Health Administration). (1992). Occupational safety and health guideline for tert-butyl alcohol (pp. 7). Cincinnati, OH: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/81-123/pdfs/0078.pdf
OSHA (Occupational Safety & Health Administration). (2006). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. (OSHA standard 1910.1000, 29 CFR). Washington, DC: U.S. Department of Labor. http://www.osha.gov/pls/oshaweb/owadisp.showdocument?ptable=STANDARDS&pid=9992
Oshiro, WM; Beasley, TE; McDaniel, KL; Taylor, MM; Evansky, P; Moser, VC, (2014). Selective cognitive deficits in adult rats after prenatal exposure to inhaled ethanol. 45: 44–58. http://www.sciencedirect.com/science/article/pii/S089203621400138X
Peter, CP; Burek, JD; van Zwieten, MJ. (1986). Spontaneous nephropathies in rats. Toxicologic Pathology 14: 91–100.3715332
Poet, TS; Valentine, JL; Borghoff, SJ. (1997). Pharmacokinetics of tertiary butyl alcohol in male and female Fischer 344 rats. Toxicology Letters 92: 179–186. 10.1016/S0378-4274(97)00056-8 9334828
Qatanani, M; Zhang, J; Moore, DD. (2005). Role of the constitutive androstane receptor in xenobiotic-induced thyroid hormone metabolism. Endocrinology 146: 995–1002. 10.1210/en.2004-1350 15564320
Rao, HV; Ginsberg, GL. (1997). A physiologically-based pharmacokinetic model assessment of methyl t-butyl ether in groundwater for a bathing and showering determination. Risk Analysis 17: 583–598. 10.1111/j.1539-6924.1997.tb00899.x 9404048
Roques, BB; Leghait J; Lacroix, MZ; Lasserre, F; Pineau, T; Viguié, C, (2013). The nuclear receptors pregnane X receptor and constitutive androstane receptor contribute to the impact of fipronil on hepatic gene expression linked to thyroid hormone metabolism. Biochemical Pharmacology 86: 997–1039. 10.1016/j.bcp.2013.08.012 23962444
Saito, A; Sasaki, T; Kasai, T; Katagiri, T; Nishizawa, T; Noguchi, T, (2013). Hepatotumorigenicity of ethyl tertiary-butyl ether with 2-year inhalation exposure in F344 rats. Archives of Toxicology 87: 905–914. 10.1007/s00204-012-0997-x 23389738
Salazar, KD; Brinkerhoff, CJ; Lee, JS; Chiu, WA. (2015). Development and application of a rat PBPK model to elucidate kidney and liver effects induced by ETBE and tert-butanol. Toxicology and Applied Pharmacology 288: 439–452. 10.1016/j.taap.2015.08.015 26341290
Sasso, AF; Schlosser, PM; Kedderis, GL; Genter, MB; Snawder, JE; Li, Z, (2013). Application of an updated physiologically based pharmacokinetic model for chloroform to evaluate CYP2E1-mediated renal toxicity in rats and mice. Toxicological Sciences 131: 360–374. 10.1093/toxsci/kfs320 23143927
Satirapoj, B; Nast CC; Adler, SG. (2012). Novel insights into the relationship between glomerular pathology and progressive kidney disease [Review]. Advances in Chronic Kidney Disease 19: 93–100. 10.1053/j.ackd.2011.12.001 22449346
Scorecard. (2014). Chemical profile for TERT-BUTYL ALCOHOL (CAS Number: 75-65-0). Available online at http://scorecard.goodguide.com/chemical-profiles/summary.tcl?edf_substance_id=+75-65-0
Seely, JC; Haseman, JK; Nyska, A; Wolf, DC; Everitt JI; Hailey, JR. (2002). The effect of chronic progressive nephropathy on the incidence of renal tubule cell neoplasms in control male F344 rats. Toxicologic Pathology 30: 681–686. 10.1080/01926230290166779 12512869
Sgambato, A; Iavicoli, I; De Paola, B; Bianchino, G; Boninsegna, A; Bergamaschi, A, (2009). Differential toxic effects of methyl tertiary butyl ether and tert-butanol on rat fibroblasts in vitro. Toxicology and Industrial Health 25: 141–151. 10.1177/0748233709104867 19458137
Short, BG; Burnett, VL; Swenberg, JA. (1986). Histopathology and cell proliferation induced by 2,2,4-trimethylpentane in the male rat kidney. Toxicologic Pathology 14: 194–203. 10.1177/019262338601400208 3764317
Short, BG; Burnett, VL; Swenberg, JA. (1989). Elevated proliferation of proximal tubule cells and localization of accumulated “alpha”2u-globulin in F344 rats during chronic exposure to unleaded gasoline or 2,2,4-trimethylpentane. Toxicology and Applied Pharmacology 101: 414–431. 10.1016/0041-008X(89)90191-9 2481346
Suzuki, M; Yamazaki, K; Kano, H; Aiso, S; Nagano, K; Fukushima, S. (2012). No carcinogenicity of ethyl tertiary-butyl ether by 2-year oral administration in rats. Journal of Toxicological Sciences 37: 1239–1246.23208438
Swenberg, JA; Lehman-McKeeman, LD. (1999). Alpha 2-urinary globulin-associated nephropathy as a mechanism of renal tubule cell carcinogenesis in male rats. In CC Capen; E Dybing; JM Rice; JD Wilbourn (Eds.), Species Differences in Thyroid, Kidney, and Urinary Bladder Carcinogenesis (pp. 95–118). Lyon, France: International Agency for Research on Cancer. http://apps.who.int/bookorders/anglais/detart1.jsp?sesslan=1&codlan=1&codcol=73&codcch=147
Takahashi, K; Lindamood, C; Maronpot, R. (1993). Retrospective study of possible alpha-2 muglobulin nephropathy and associated cell proliferation in male Fischer 344 rats dosed with t-butyl alcohol. Environmental Health Perspectives 101: 281–285.7516874
Tang, GH; Wang, J; Zhuang, Z. (1997). [Cytotoxicity and genotoxicity of methyl tert-butyl ether and its metabolite to human leukemia cells]. Zhonghua Yufang Yixue Zazhi 31: 334–337.9863065
U.S EPA (U.S. Environmental Protection Agency). (2016). Model files for tert-butanol and ETBE. Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report] (pp. 1–395). (EPA/600/6-87/008). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1991a). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat (pp. 1–136). (EPA/625/3-91/019F). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?search0uery=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (1991b). Guidelines for developmental toxicity risk assessment (pp. 1–71). (EPA/600/FR-91/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=23162
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report] (pp. 1–409). (EPA/600/8-90/066F). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment (pp. 1–143). (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-11/documents/guidelinesreprotoxicity.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1997). Drinking water advisory: Consumer acceptability advice and health effects analysis on methyl tertiary-butyl ether (MTBE) [EPA Report] (pp. 1–42). Washington, DC: U.S. Environmental Protection Agency, Office of Water. http://nepis.epa.gov/Exe/ZyNET.exe/20003HO4.TXT?ZyActionD=ZyDocument&Client=EPA&Index=1995+Thru+1999&Docs=&0uery=&Time=&EndTime=&SearchMethod=1&TocRestrict=n&.Toc=&TocEntry=&QField=&QFieldYear=&QFieldMonth=&QFieldDay=&IntQFieldOp=0&ExtQFieldOp=0&Xml0uery=&File=D%3A%5Czyfiles%5CIndex%20Data%5C95thru99%5CTxt%5C00000009%5C20003HO4.txt&User=ANONYMOUS&Password=anonymous&SortMethod=h%7C-&MaximumDocuments=1&FuzzyDegree=0&ImageQualitv=r75g8/r75g8/x150y150g16/i425&Display=p%7Cf&DefSeekPage=x&SearchBack=ZyActionL&Back=ZyActionS&BackDesc=Results%20page&MaximumPages=1&ZyEntry=1&SeekPage=x&ZyPURL
U.S. EPA (U.S. Environmental Protection Agency). (1998a). Assessment of thyroid follicular cell tumors [EPA Report] (pp. 1–51). (EPA/630/R-97/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-11/documents/thyroid.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1998b). Guidelines for neurotoxicity risk assessment. Federal Register 63: 26926–26954.
U.S. EPA (U.S. Environmental Protection Agency). (2000). Science policy council handbook: Risk characterization handbook [EPA Report]. (EPA/100/B-00/002). Washington, D.C.: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/risk/risk-characterization-handbook
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes (pp. 1–192). (EPA/630/P-02/002F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/osa/review-reference-dose-and-reference-concentration-processes
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for Carcinogen Risk Assessment [EPA Report]. (EPA/630/P-03/001B). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2013-09/documents/cancerguidelinesfinal3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Guidelines for carcinogen risk assessment [EPA Report] (pp. 1–166). (EPA/630/P-03/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www2.epa.gov/osa/guidelines-carcinogen-risk-assessment
U.S. EPA (U.S. Environmental Protection Agency). (2005c). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens (pp. 1–125). (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
U.S. EPA (U.S. Environmental Protection Agency). (2006). Approaches for the application of physiologically based pharmacokinetic (PBPK) models and supporting data in risk assessment (Final Report) [EPA Report] (pp. 1–123). (EPA/600/R-05/043F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=157668
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose (pp. 1–50). (EPA/100/R-11/0001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark dose technical guidance (pp. 1–99). (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Releases: Facility report. Toxics release inventory. Available online at https://enviro.epa.gov/triexplorer/trirelease.chemical
U.S. EPA (U.S. Environmental Protection Agency). (2012c). Toxicological review of tetrahydrofuran. In support of summary information on the integrated risk information system (IRIS) (pp. 1–207). (EPA/635/R-11/006F). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2014a). 2012 Chemical data reporting results. Available online at https://www.epa.gov/chemicals-under-tsca
U.S. EPA (U.S. Environmental Protection Agency). (2014b). Guidance for applying quantitative data to develop data-derived extrapolation factors for interspecies and intraspecies extrapolation. (EPA/100/R-14/002F). Washington, DC; Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2015-01/documents/ddef-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2016). TRI explorer (2014 dataset released March 2016). Washington, D.C. Retrieved from https://www.epa.gov/toxics-release-inventory-tri-program
Williams, TM; Borghoff, SJ. (2001). Characterization of tert-butyl alcohol binding to “alpha”2u-globulin in F-344 rats. Toxicological Sciences 62: 228–235. 10.1093/toxsci/62.2.228 11452135
Yuan, Y; Wang, HF; Sun, HF; Du, HF; Xu, LH; Liu, YF, (2007). Adduction of DNA with MTBE and TBA in mice studied by accelerator mass spectrometry. Environmental Toxicology 22: 630–635. 10.1002/tox.20295 18000852
Zeiger, E; Anderson, B; Haworth, S; Lawlor, T; Mortelmans, K; Speck, W. (1987). Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environmental Mutagenesis 9: 1–109. 10.1002/em.2860090602
Zoja, C; Abbate, M; Remuzzi, G. (2015). Progression of renal injury toward interstitial inflammation and glomerular sclerosis is dependent on abnormal protein filtration [Review]. Nephrology, Dialysis, Transplantation 30: 706–712. 10.1093/ndt/gfu261