# PREFACE

This Toxicological Review critically reviews the publicly available studies on tert-butyl alcohol (tert-butanol) to identify its adverse health effects and to characterize exposure-response relationships. The assessment examined all effects by oral and inhalation routes of exposure and includes a noncancer oral reference dose (RfD), a noncancer inhalation reference concentration (RfC), a cancer weight-of-evidence descriptor, and a cancer dose-response assessment. It was prepared under the auspices of the U.S. Environmental Protection Agency’s (EPA’s) Integrated Risk Information System (IRIS) Program. This is the first IRIS assessment for this chemical.

Toxicological Reviews for tert-butanol and ethyl tert-butyl ether (ETBE) were developed simultaneously because they have several overlapping scientific aspects:

- tert-Butanol is one of the primary metabolites of ETBE, and some of the toxicological effects of ETBE are attributed to tert-butanol. Therefore, data on ETBE are considered informative for the hazard identification and dose-response assessment of tert-butanol, and vice versa.
- The scientific literature for the two chemicals includes data on alpha 2u-globulin-related nephropathy; therefore, a common approach was employed to evaluate these data as they relate to the mode of action for kidney effects.
- A combined physiologically based pharmacokinetic (PBPK) model for tert-butanol and ETBE in rats was applied to support the dose-response assessments for these chemicals.

A public meeting was held in December 2013 to obtain input on preliminary materials for tert-butanol, including draft literature searches and associated search strategies, evidence tables, and exposure-response arrays prior to the development of the IRIS assessment. All public comments provided were taken into consideration in developing the draft assessment.

A public science meeting was held on June 30, 2016 to provide the public an opportunity to engage in early discussions on the draft IRIS Toxicological Review and the draft charge to the peer review panel prior to release for external peer review. The complete set of public comments, including the slides presented at the June 2016 public science meeting, is available on the docket at http://www.regulations.gov (Docket ID No. EPA-HQ-ORD-2013-1111 (https://www.regulations.gov/docket/EPA-HQ-ORD-2013-0111)).

Organ/system-specific reference values are calculated based on kidney and thyroid toxicity data. These reference values could be useful for cumulative risk assessments that consider the combined effect of multiple agents acting on the same biological system.

This assessment was conducted in accordance with EPA guidance, which is cited and summarized in the Preamble to IRIS Toxicological Reviews. The findings of this assessment and related documents produced during its development are available on the IRIS website (http://www.epa.gov/iris). Appendices for toxicokinetic information, PBPK modeling, genotoxicity study summaries, dose-response modeling, and other information are provided as Supplemental Information to this Toxicological Review. For additional information about this assessment or for general questions regarding IRIS, please contact EPA’s IRIS Hotline at 202-566-1676 (phone), 202-566-1749 (fax), or hotline.iris@epa.gov.

## Uses

tert-Butanol is primarily an anthropogenic substance that is produced in large quantities (HSDB, 2007) from several precursors, including 1-butene, isobutylene, acetyl chloride and dimethylzinc, and tert-butyl hydroperoxide. The domestic production volume of tert-butanol, including imports, was approximately 4 billion pounds in 2012 (U.S. EPA, 2014a).

tert-Butanol has been used as a fuel oxygenate, an octane booster in unleaded gasoline, and a denaturant for ethanol. From 1997 to 2005, the annual tert-butanol volume found in gasoline ranged from approximately 4 million to 6 million gallons. During that time, larger quantities were used to make methyl tert-butyl ether (MTBE) and ETBE. MTBE and ETBE are fuel oxygenates that were used in the United States prior to 2007 at levels of more than 2 billion gallons annually. Current use levels of MTBE and ETBE in the United States are much lower, but the use in Europe and Asia remains strong.^1^ Some states have banned MTBE in gasoline due to concerns of groundwater contamination from gasoline leaks and spills.

tert-Butanol has been used for a variety of other purposes, including as a dehydrating agent and solvent. It is added to lacquers, paint removers, and nail enamels and polishes. tert-Butanol also is used to manufacture methyl methacrylate plastics and flotation devices. It is used in the manufacture of food flavoring, and, because of its camphor-like aroma, it also is used to create artificial musk, fruit essences, and perfume (HSDB, 2007). tert-Butanol is used in coatings on metal and paperboard food containers (CalEPA, 1999) and industrial cleaning compounds and can be used for chemical extraction in pharmaceutical applications (HSDB, 2007).

## Fate and Transport

### Soil

tert-Butanol is expected to be highly mobile in soil due to its low affinity for soil organic matter. Rainwater or other water percolating through soil is expected to dissolve and transport most tert-butanol present in soil, potentially leading to groundwater contamination. Based on its vapor pressure, tert-butanol’s volatilization from soil surfaces is expected to be an important dissipation process (HSDB, 2007). As a tertiary alcohol, tert-butanol is expected to degrade more slowly in the environment compared to primary (e.g., ethanol) or secondary (e.g., isopropanol) alcohols. In anoxic soil conditions, the half-life of tert-butanol is estimated to be months (approximately 200 days). Microbial degradation rates are increased in soils supplemented with nitrate and sulfate nutrients (HSDB, 2007).

### Water

tert-Butanol is expected to volatilize from water surfaces within 2 to 29 days and does not readily adsorb to suspended solids and sediments in water (HSDB, 2007). Biodegradation in aerobic water occurs over weeks to months and in anaerobic aquatic conditions, the biodegradation rate decreases. Bioconcentration of tert-butanol in aquatic organisms is low (HSDB, 2007).

### Air

tert-Butanol primarily exists as a vapor in the ambient atmosphere. Vapor-phase tert-butanol is degraded in the atmosphere by reacting with photochemically produced hydroxyl radicals and has a half-life of 14 days (HSDB, 2007).

## Occurrence in the Environment

The Toxics Release Inventory (TRI) program National Analysis Report estimated that more than 1 million pounds of tert-butanol have been released into the soil from landfills, land treatment, underground injection, surface impoundments, and other land disposal sources. In 2014, the TRI program also reported 1,845,773 pounds of tert-butanol released into the air, discharged to bodies of water, disposed of at the facility to land, and disposed of in underground injection wells (U.S. EPA, 2016). Total off-site disposal or other releases of tert-butanol amounted to 67,060 pounds (U.S. EPA, 2016). In California, air emissions of tert-butanol from stationary sources are estimated to be at least 27,000 pounds per year, based on data reported by the state’s Air Toxics Program (Scorecard, 2014).

tert-Butanol has been identified in drinking water wells throughout the United States (HSDB, 2007). California’s Geotracker Database^2^ lists 3,496 detections of tert-butanol in groundwater associated with contaminated sites in that state since 2011. tert-Butanol also has been detected in drinking water wells in the vicinity of landfills (U.S. EPA, 2012b). Additionally, MTBE and ETBE leaking from underground storage tanks can degrade to form tert-butanol in soils (HSDB, 2007). The industrial chemical tert-butyl acetate also can degrade to form tert-butanol in the environment and as a metabolite in animals post exposure.

Ambient outdoor air concentrations of tert-butanol vary according to proximity to urban areas (HSDB, 2007).

## General Population Exposure

tert-Butanol exposure can occur in many different settings. Releases from underground storage tanks could result in exposure for people who get their drinking water from wells. Due to its high environmental mobility and resistance to biodegradation, tert-butanol has the potential to contaminate and persist in groundwater and soil (HSDB, 2007).

Ingestion of contaminated food can be a source of tert-butanol exposure through its use as a coating in metallic and paperboard food containers (CalEPA, 1999), and tert-butanol has been detected in food (HSDB, 2007). Internal exposure to tert-butanol also can occur by ingestion of MTBE or ETBE because tert-butanol is a metabolite of these compounds (NSF International, 2003).

Other human exposure pathways include inhalation, breast milk, and, to a lesser extent, dermal contact. Inhalation exposure can occur because of the chemical’s volatility and release from industrial processes, consumer products, and contaminated sites (HSDB, 2007). tert-Butanol has been identified in mother’s milk (HSDB, 2007). Dermal contact is a viable route of exposure through handling consumer products containing tert-butanol (NSF International, 2003).

## Assessments by Other National and International Health Agencies

Toxicity information on tert-butanol has been evaluated by the National Institute for Occupational Safety and Health (NIOSH, 2007), the Occupational Safety and Health Administration (OSHA, 2006), and the Food and Drug Administration (FDA, 2015a, b). The results of these assessments are presented in Appendix A of the Supplemental Information to this Toxicological Review. Of importance to recognize is that these earlier assessments could have been prepared for different purposes and might use different methods. In addition, newer studies have been included in the IRIS assessment.

1 http://www.ihs.com/products/chemical/planning/ceh/gasoline-octane-improvers.aspx.

2 http://geotracker.waterboards.ca.gov/.