# LITERATURE SEARCH STRATEGY | STUDY SELECTION AND EVALUATION

A literature search and screening strategy was used to identify literature characterizing the health effects of tert-butanol. This strategy consisted of a broad search of online scientific databases and other sources using the most common synonyms and trade names to identify all potentially pertinent studies. In subsequent steps, references were screened to exclude papers not pertinent to an assessment of the health effects of tert-butanol, and the remaining references were sorted into categories for further evaluation. This section describes the literature search and screening strategy in detail.

The chemical-specific search was conducted in four core online scientific databases, PubMed, Web of Science, and Toxline, as well as Toxic Substances Control Act Test Submissions (TSCATS) through December 2016, using the keywords and limits described in Table LS-1. The overall literature search approach is shown graphically in Figure LS-1. Eight more citations were obtained using additional search strategies described in Table LS-2. After electronically eliminating duplicates from the citations retrieved through these databases, 3,138 unique citations were identified.

The resulting 3,138 citations were screened for pertinence and separated into categories as presented in Figure LS-1 using the title and either abstract or full text, or both, to examine the health effects of tert-butanol exposure. The inclusion and exclusion criteria used to screen the references and identify sources of health effects data are provided in Table LS-3;

- 12 references were identified as “Sources of Health Effects Data” and were considered for data extraction to evidence tables and exposure-response arrays.
- 202 references were identified as “Sources of Mechanistic and Toxicokinetic Data” and “Sources of Supporting Health Effects Data”; these included 41 studies describing physiologically based pharmacokinetic (PBPK) models and other toxicokinetic information, 73 studies providing genotoxicity and other mechanistic information, 1 human case report, 74 irrelevant exposure paradigms (including acute, dermal, eye irritation, and injection studies), 6 preliminary toxicity studies, and 7 physical dependency studies. Information from these studies was not extracted into evidence tables; however, these studies were considered as support for assessing tert-butanol health effects, for example, evaluation of mode of action and extrapolation of experimental animal findings to humans. Additionally, although still considered sources of health effects information, studies investigating the effects of acute and direct chemical exposures are generally less pertinent for characterizing health hazards associated with chronic oral and inhalation exposure. Therefore, information from these studies was not considered for extraction into evidence tables. Nevertheless, these studies were still evaluated as possible sources of supplementary health effects information.
- 128 references were identified as “Secondary Literature and Sources of Contextual Information” (e.g., reviews and other agency assessments); these references were retained as additional resources for developing the Toxicological Review.
- 2,796 references were identified as not being pertinent (not on topic) to an evaluation of the health effects of tert-butanol and were excluded from further consideration (see Figure LS-1 for exclusion categories and Table LS-3 for exclusion criteria). For example, health effect studies of gasoline and tert-butanol mixtures were not considered pertinent to the assessment because the separate effects of the gasoline or other chemical components could not be determined. Retrieving a large number of references that are not on topic is a consequence of applying an initial search strategy designed to cast a wide net and to minimize the possibility of missing potentially relevant health effects data.

The complete list of references and the sorting of these materials can be found on the tert-butanol project page of the Health and Environmental Research Online (HERO) website at https://hero.epa.gov/index.cfm/project/page/projectid/1543.

## SELECTION OF STUDIES FOR INCLUSION IN EVIDENCE TABLES

To summarize the important information systematically from the primary health effects studies in the tert-butanol evidence base, evidence tables were constructed in a standardized tabular format as recommended by NRC (2011). Studies were arranged in the evidence tables by effect, species, duration, and design, and not by quality. Of the studies retained after the literature search and screen, 12 studies were identified as “Sources of Health Effects Data” and were considered for extraction into evidence tables for hazard identification in Section 1. Initial review found two references (Cirvello et al., 1995; Lindamood et al., 1992) to be publications of the NTP (1995) data prior to the release of the final National Toxicology Program (NTP) report. One publication (Takahashi et al., 1993) in the “Supplementary Studies” category also was based on data from the NTP report. The interim publications and the final NTP report differed. The finalized NTP (1995) report was considered the more complete and accurate presentation of the data; therefore, this report was included in the evidence tables, and the Cirvello et al. (1995), Takahashi et al. (1993), and Lindamood et al. (1992) papers were not. Data from the remaining 10 references in the “Sources of Health Effects Data” category were extracted into evidence tables.

Supplementary studies that contain pertinent information for the Toxicological Review and augment hazard identification conclusions, such as genotoxic and mechanistic studies, studies describing the kinetics and disposition of tert-butanol absorption and metabolism, pilot studies, and one case report, were not included in the evidence tables. Short-term and acute studies (including an 18-day study and a 14-day study by NTP), which used oral and inhalation exposures performed primarily in rats, did not differ qualitatively from the results of the longer term studies (i.e., ≥30-day exposure studies). These were grouped as supplementary studies, however, because the evidence base of chronic and subchronic rodent studies was considered sufficient for evaluating chronic health effects of tert-butanol exposure. Additionally, studies of effects from chronic exposure are most pertinent to lifetime human exposure (i.e., the primary characterization provided by Integrated Risk Information System [IRIS] assessments) and are the focus of this assessment. Such supplementary studies are discussed in the narrative sections of Section 1 and are described in sections such as the “Mode of Action Analysis” to augment the discussion or presented in appendices, if they provide additional information.

Figure LS-1 Summary of literature search and screening process for tert-butanol

Table LS-1 Details of the search strategy employed for tert-butanol

Database (search date) | Keywords | Limits
PubMed; (12/20/2012); (4/17/2014); (5/13/2015); (12/31/2016); (7/5/2019)^a^ | tert-butanol OR 75-65-0[rn] OR “t-butyl hydroxide” OR “2-methyl-2-propanol” OR “trimethyl carbinol” OR “t-butyl alcohol” OR tert-butanol OR “tert-butyl alcohol” OR tert-butyl alcohol[mesh] | None
Web of Science; (12/20/2012); (4/17/2014); (5/13/2015); (12/31/2016); (7/5/2019)^a^ | Topic = (tert-butanol OR 75-65-0 OR “t-butyl hydroxide” OR “2-methyl-2-propanol” OR “trimethyl carbinol” OR “t-butyl alcohol” OR “tert-butanol” OR “tert-butyl alcohol”) | Refined by: Research Areas = (cell biology OR respiratory system OR microscopy OR biochemistry molecular biology OR gastroenterology OR hepatology OR public environmental occupational health OR oncology OR physiology OR cardiovascular system cardiology OR toxicology OR life sciences biomedicine other topics OR hematology OR pathology OR neurosciences neurology OR developmental biology)
Toxline (includes TSCATS); (1/11/2013); (4/17/2014); (5/13/2015); (12/31/2016); (7/5/2019)^a^ | tert-butanol OR 75-65-0 [rn] OR t-butyl hydroxide OR 2-methyl-2-propanol OR trimethyl carbinol OR t-butyl alcohol OR tert-butyl alcohol | Not PubMed
TSCATS2; (1/4/2013); (4/17/2014); (5/13/2015); (12/31/2016) | 75-65-0 | None

a See post-peer-reviewed literature search update section.

Table LS-2 Summary of additional search strategies for tert-butanol

Approach used | Source(s) | Date performed | Number of additional references identified
Manual search of citations from reviews and public comments | Review article: McGregor (2010). Tertiary-butanol: A toxicological review. Crit Rev Toxicol 40(8): 697–727. | 1/2013 | 5
Manual search of citations from reviews and public comments | Review article: Chen (2005). Amended final report of the safety assessment of t-butyl alcohol as used in cosmetics. Int J Toxicol 24(2): 1–20. | 1/2013 | 2
Manual search of citations from reviews and public comments | Public comment article: Borghoff et al. (2016) | 10/2016 | 1
Manual search of citations from reviews conducted by other international and federal agencies | IPCS (1987). Butanols: Four isomers: 1-butanol, 2-butanol, tert-butanol, isobutanol [WHO EHC]. Geneva, Switzerland: World Health Organization. | 1/2013 | None
Manual search of citations from reviews conducted by other international and federal agencies | OSHA (1992). Occupational safety and health guideline for tert-butyl alcohol. Cincinnati, OH: Occupational Safety and Health Administration. | 1/2013 | None

Table LS-3 Inclusion-exclusion criteria

| Inclusion criteria | Exclusion criteria/Supplemental material^a^
Population | - Humans.; - Standard mammalian animal models, including rat, mouse, rabbit, guinea pig, monkey, dog. | - Ecological species.^a^; - Nonmammalian species.^a^
Exposure | - Exposure is to tert-butanol.; - Exposure is measured in an environmental medium (e.g., air, water, diet).; - Exposure via oral, inhalation, or dermal routes. | - Study population is not exposed to tert-butanol.; - Exposure to a mixture only (e.g., gasoline containing tert-butanol).; - Exposure via injection (e.g., intravenous).; - Exposure pattern less relevant to chronic health effects (e.g., acute).
Outcome | - Study includes a measure of one or more health effect endpoints, including effects on the nervous, musculoskeletal, cardiovascular, immune, hematological, endocrine, respiratory, urinary, and gastrointestinal systems; reproduction; development; liver; kidney; eyes; skin; and cancer.; - Physical dependency studies where withdrawal symptoms were evaluated after removal of tert-butanol treatment.
Other | | Not on topic, including:; - Abstract only, editorial comments were not considered further.; - Bioremediation, biodegradation, or environmental fate of tert-butanol, including evaluation of wastewater treatment technologies and methods for remediation of contaminated water and soil.; - Chemical, physical, or fuel chemistry studies.; - Analytical methods for measuring/detecting/remotely sensing tert-butanol.; - Use of tert-butanol as a solvent or methodology for testing unrelated to tert-butanol.; - Not chemical specific: Studies that do not involve testing of tert-butanol.; - Foreign language studies that were not considered further because, based on title or abstract, judged not potentially relevant.; - QSAR studies.

EHC= Environmental Health Criteria; WHO = World Health Organization.

a Studies that met this exclusion criterion were considered supplemental (i.e., not considered a primary source of health effects data but were retained as potential sources of contextual information).

## DATABASE EVALUATION

For this draft assessment, 12 references reported on experimental animal studies that comprised the primary sources of health effects data; no studies were identified that evaluated humans exposed to tert-butanol (e.g., cohort studies, ecological studies). The animal studies were evaluated using the study quality considerations outlined in the Preamble, considering aspects of design, conduct, or reporting that could affect the interpretation of results, overall contribution to the synthesis of evidence, and determination of hazard potential as noted in various EPA guidance documents (U.S. EPA, 2005b, 1998a, 1996, 1991b). The objective was to identify the stronger, more informative studies based on a uniform evaluation of quality characteristics across studies of similar design. As stated in the Preamble, these studies were evaluated to identify the suitability of the study based on:

- Study design.
- Nature of the assay and validity for its intended purpose.
- Characterization of the nature and extent of impurities and contaminants of tert-butanol administered, if applicable.
- Characterization of dose and dosing regimen (including age at exposure) and their adequacy to elicit adverse effects, including latent effects.
- Sample sizes and statistical power to detect dose-related differences or trends.
- Ascertainment of survival, vital signs, disease or effects, and cause of death.
- Control of other variables that could influence the occurrence of effects.

Additionally, several general considerations, presented in Table LS-4, were used in evaluating the animal studies. Much of the key information for conducting this evaluation can be determined based on study methods and how the study results were reported. Importantly, the evaluation at this stage does not consider the direction or magnitude of any reported effects.

EPA considered statistical tests to evaluate whether the observations might be due to chance. The standard for determining statistical significance of a response is a trend test or comparison of outcomes in the exposed groups against those of concurrent controls. Studies that did not report statistical testing were identified and, when appropriate, statistical tests were conducted by EPA.

Information on study features related to this evaluation is reported in evidence tables and documented in the synthesis of evidence. Discussion of study strengths and limitations are included in the text, where relevant. If EPA’s interpretation of a study differs from that of the study authors, the draft assessment discusses the basis for the difference.

### Experimental Animal Studies

The experimental animal studies, comprised entirely of studies performed in rats and mice, were associated with drinking water, oral gavage, liquid diets (i.e., maltose/dextrin), and inhalation exposures to tert-butanol. With the exception of neurodevelopmental studies, these studies were conducted according to Organisation for Economic Co-operation and Development (OECD) Good Laboratory Practice (GLP) guidelines; they used well-established methods, were well reported, and evaluated an extensive range of endpoints and histopathological data. These studies include 2-year bioassays using oral exposures in rats and mice, two subchronic drinking water studies in rats and one in mice, an inhalation subchronic study in rats and mice, a reevaluation of the NTP (1995) rat data, two oral developmental studies, two inhalation developmental studies, and a single one-generation reproductive study that also evaluates other systemic effects (see Table LS-5). For the body of available studies, detailed discussion of any identified methodological concerns precedes each endpoint evaluated in the hazard identification section. Overall, the experimental animal studies of tert-butanol involving repeated oral or inhalation exposure were considered to be of acceptable quality, and whether yielding positive, negative, or null results, were considered in assessing the evidence for health effects associated with chronic exposure to tert-butanol.

Table LS-4 Considerations for evaluation of experimental animal studies

Methodological feature | Considerations (relevant information extracted into evidence tables)
Test animal | Suitability of the species, strain, sex, and source of the test animals
Experimental design | Suitability of animal age/lifestage at exposure and endpoint testing; periodicity and duration of exposure (e.g., h/d, d/wk); timing of endpoint evaluations; and sample size and experimental unit (e.g., animals, dams, litters)
Exposure | Characterization of test article source, composition, purity, and stability; suitability of the control (e.g., vehicle control); documentation of exposure techniques (e.g., route, chamber type, gavage volume); verification of exposure levels (e.g., consideration of homogeneity, stability, analytical methods)
Endpoint evaluation | Suitability of specific methods for assessing the endpoint(s) of interest
Results presentation | Data presentation for endpoint(s) of interest (including measures of variability) and for other relevant endpoints needed for interpreting results (e.g., maternal toxicity, decrements in body weight relative to organ weight)

Table LS-5 Summary of experimental animal evidence base

Study category | Study duration, species/strain, and administration method
Chronic | 2-yr study in F344 rats (drinking water); NTP (1995); 2-yr study in B6C3F1 mice (drinking water); NTP (1995)
Subchronic | 13-wk study in B6C3F1 mice (drinking water); NTP (1995); 13-wk study in F344 rats (drinking water); NTP (1995); 13-wk study in F344 rats (inhalation); NTP (1997); 13-wk study in B6C3F1 mice (inhalation); NTP (1997); 10-wk study in Wistar rats (drinking water); Acharya et al. (1997), Acharya et al. (1995)
Reproductive | One-generation reproductive toxicity study in Sprague-Dawley rats (gavage); Huntingdon Life Sciences (2004)
Developmental | Developmental study (GD 6–20) in Swiss Webster mice (diet); Daniel and Evans (1982); Developmental study (GD 6–18) in CBA/J mice (drinking water); Faulkner et al. (1989); Developmental study (GD 6–18) in C57BL/6J mice (drinking water); Faulkner et al. (1989); Developmental study (GD 1–19) in Sprague-Dawley rats (inhalation); Nelson et al. (1989)
Neurodevelopmental | Neurodevelopmental study (GD 6–20) in Swiss Webster mice (diet); Daniel and Evans (1982); Neurodevelopmental study (GD 1–19) in Sprague-Dawley rats (inhalation); Nelson et al. (1991)

GD = gestation day.

### Post-Peer-Review Literature Search Update

A post-peer-review literature search update was conducted in PubMed, Web of Science, and Toxline for the period January 2017 to July 2019 using a search strategy consistent with previous literature searches (see Table LS-1). The documentation and results for the literature search and screen, including the specific references identified using each search strategy and tags assigned to each reference based on the manual screen, can be found on the HERO website on the tert-butanol project page at: (https://hero.epa.gov/hero/index.cfm/proiect/page/proiectid/1543).

Consistent with the IRIS Stopping Rules (https://www.epa.gov/sites/production/files/2014-06/documents/irisstoppingrules.pdf) manual screening of the literature search update focused on identifying new studies that might change a major conclusion of the assessment. The last formal literature search was in 2019 while the draft was in external peer review, after which the literature was monitored in PubMed through January 2021. No animal bioassays or epidemiological studies were identified in the post-peer-review literature searches that would change any major conclusions in the assessment.