# AUTHORS | CONTRIBUTORS | REVIEWERS

Assessment Team
Janice S. Lee, Ph.D. (Chemical Manager); James A. Weaver (Co-Chemical Manager); Kathleen Newhouse, M.S.* | EPA; Office of Research and Development; Center for Public Health and Environmental Assessment; Research Triangle Park, NC; *Washington, DC
Keith Salazar, Ph.D. | Former Co-Chemical Manager; EPA/ORD/NCEA; Currently with EPA, Office of Chemical Safety and Pollution; Prevention, Office of Pollution Prevention and Toxics, Risk; Assessment Division; Washington, DC
Chris Brinkerhoff, Ph.D. | Former ORISE Postdoctoral Fellow at EPA/ORD/NCEA; Currently with EPA, Office of Children’s Health Protection,; Office of the Administrator; Washington, DC
Contributors
Christine Cai, M.S.*; Catherine Gibbons, Ph.D.*; Karen Hogan, M.S.*; Andrew Hotchkiss, Ph.D.; Samantha Jones, Ph.D.*; Channa Keshava, Ph.D.; Amanda Persad, Ph.D.; Alan Sasso, Ph.D.*; Paul Schlosser, Ph.D. | EPA; Office of Research and Development; Center for Public Health and Environmental Assessment; Research Triangle Park, NC; *Washington, DC
Vincent Cogliano, Ph.D.; Jason Fritz, Ph.D. | (previously with) EPA National Center for Environmental Assessment
Charles Wood, Ph.D. | (previously with) EPA National Health and Environmental Effects Research Lab
Production Team
Hillary Hollinger; Maureen Johnson; Ryan Jones; Dahnish Shams; Vicki Soto; Samuel Thacker; Erin Vining | EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Contractor Support
Robyn Blain, Ph.D.; Michelle Cawley, M.L.S., M.A.*; Ami Gordon, M.P.H.; Cara Henning, Ph.D.*; Tao Hong, Ph.D.; William Mendez, Jr., Ph.D.; Pam Ross, M.S.P.H. | ICF; Fairfax, VA; *Research Triangle Park, NC
Executive Direction
Wayne E. Cascio, M.D. (CPHEA Director); Samantha Jones, Ph.D. (CPHEA Associate Director)*; Kristina Thayer, Ph.D. (CPAD Director); Andrew Kraft, Ph.D. (CPAD Senior Science Advisor)*; Paul White, Ph.D. (CPAD Senior Science Advisor)*; Ravi Subramaniam, Ph.D. (CPAD Branch Chief)* | EPA/ORD/CPHEA; Research Triangle Park, NC; *Washington, DC
Internal Review Team
General Toxicology Workgroup; Inhalation Workgroup; Neurotoxicity Workgroup; Pharmacokinetics Workgroup; Reproductive and Developmental; Toxicology Workgroup; Statistical Workgroup; Toxicity Pathways Workgroup; Executive Review Committee | EPA; Office of Research and Development; Center for Public Health and Environmental Assessment; Washington, DC; Research Triangle Park, NC; Cincinnati, OH

## Reviewers

This assessment was provided for review to scientists in EPA’s Program and Region Offices. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection
  Office of Land and Emergency Management
  Region 2, New York, NY
  Region 8, Denver, CO

This assessment was provided for review to other federal agencies and the Executive Office of the President. Comments were submitted by:

Department of Health and Human Services/Agency for Toxic Substances and Disease Registry
Department of Health and Human Services/National Institute of Environmental Health
Sciences/National Toxicology Program
Executive Office of the President/Office of Management and Budget

This assessment was released for public comment on May 16, 2016 and comments were due on July 15, 2016. The public comments are available on Regulations.gov. A summary and EPA’s disposition of the comments from the public is available in the revised external review draft assessment on the IRIS website. Comments were received from the following entities:

Marcy Banton, DVM, Ph.D. | LyondellBasell
Patrick Beatty, Ph.D. | American Petroleum Institute
Nancy Beck, Ph.D. | American Chemistry Council
Susan Borghoff, Ph.D. | Tox Strategies, on behalf of LyondellBasell
James Bus, Ph.D. | Exponent, on behalf of LyondellBasell
Samuel Cohen, M.D., Ph.D. | University of Nebraska
Jeff Fowles, Ph.D. | Tox-Logic Consulting
Lawrence Lash, Ph.D. | Wayne State University
Fukumi Nishimaki, Ph.D. | Japan Petroleum Energy Center

A public science meeting was held on June 30, 2016 to obtain public input on the IRIS Toxicological Review of tert-Butanol (Public Comment Draft). Public commenters, stakeholders, and members of the scientific community were joined by independent experts identified by the National Academies’ National Research Council (identified by * below) in a discussion of key science topics. Discussants and public commenters were:

Marcy Banton, DVM, Ph.D. | LyondellBasell
Nancy Beck, Ph.D. | American Chemistry Council
Susan Borghhoff, Ph.D. | ToxStrategies, Inc., on behalf of LyondellBasell
James Bus, Ph.D. | Exponent, on behalf of LyondellBasell
Sheue-yann Chang, Ph.D. * | NIH/National Cancer Institute
Samuel Cohen, M.D., Ph.D. * | University of Nebraska
Jeff Fowles, Ph.D. | Tox-Logic, LLC, on behalf of ExxonMobil
Gordon Hard, Ph.D., DSc | On behalf of LyondellBasell
Lawrence Lash, Ph.D. * | Wayne State University
Fukumi Nishimaki, Ph.D. | Japan Petroleum Energy Center
Thomas Rosol, DVM, Ph.D., MBA * | Ohio State University
Jerrold Ward, DVM * | Global Vet Pathology

This assessment was peer reviewed by independent, expert scientists external to EPA convened by EPA’s Science Advisory Board (SAB). A peer-review meeting was held on August 15-17, 2017. The report of the SAB’s review of the EPA’s Draft Toxicological Review of tert-Butanol, dated February 27, 2019, is available on the IRIS website. A summary and EPA’s disposition of the comments received from the SAB is included in Appendix E.

Janice E. Chambers, Ph.D. (chair) | Mississippi State University, MS
Hugh A. Barton, Ph.D. | Pfizer, Inc., Groton, CT
Janet Benson, Ph.D. | Lovelace Biomedical, Albuquerque, NM
Trish Berger, Ph.D. | University of California, Davis, Davis, CA
John Budroe, Ph.D. | Office of Environmental Health Hazard Assessment, Oakland, CA
James V. Bruckner, Ph.D. | University of Georgia, Athens, GA
Karen Chou, Ph.D. | Michigan State University, East Lansing, MI
Harvey Clewell, Ph.D. | Ramboll Environment and Health, Research Triangle Park, NC
Deborah Cory-Slechta, Ph.D. | University of Rochester, Rochester, NY
Bevin Engelward, Ph.D. | Massachusetts Institute of Technology, Cambridge, MA
Jeffrey Fisher, Ph.D. | U.S. Food and Drug Administration, Jefferson, AR
William Michael Foster, Ph.D. | Independent Consultant, Durham, NC
Alan Hoberman, Ph.D. | Charles River Laboratories, Inc., Horsham, PA
Tamarra James-Todd, Ph.D. | Harvard University, Boston, MA
Lawrence Lash, Ph.D. | Wayne State University, Detroit, MI
Marvin Meistrich, Ph.D. | Anderson Cancer Center, University of Texas, Houston, TX
Maria Morandi, Ph.D. | Independent Consultant, Houston, TX
Isaac Pessah, Ph.D. | University of California, Davis, CA
Lorenz Rhomberg, Ph.D. | Gradient, Cambridge, MA
Stephen M. Roberts, Ph.D. | University of Florida, Gainesville, FL; New Jersey Department of Environmental Protection/
Alan Stern, Ph.D. | University of Medicine and Dentistry of New Jersey-Robert Wood Johnson Medical School, Trenton, NJ

The postexternal review draft of the assessment was provided for review to scientists in EPA’s Program and Regional Offices, and to other federal agencies and the Executive Office of the President (EOP). A summary and EPA’s disposition of major comments from the other federal agencies and EOP is available on the IRIS website. Comments were submitted by:

EPA | Office of Water
EPA | Office of Land and Emergency Management
The National Institute for Occupational Safety and Health
Office of Management and Budget