# 2 DOSE-RESPONSE ANALYSIS

## 2.1 ORAL REFERENCE DOSE FOR EFFECTS OTHER THAN CANCER

The oral reference dose (RfD, expressed in units of mg/kg-day) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. The RfD can be derived from a no-observed-adverse-effect level (NOAEL), lowest-observed-adverse-effect level (LOAEL), or the benchmark dose lower confidence limit (BMDL), with uncertainty factors (UFs) generally applied to reflect limitations of the data used.

### 2.1.1 Identification of Studies and Effects for Dose-Response Analysis

EPA identified kidney effects as a potential human hazard of tert-butanol exposure (see Section 1.2.1). Studies within this effect category were evaluated using general study quality characteristics [as discussed in Section 4 of the Preamble; see also U.S. EPA (2002)] to help inform the selection of studies from which to derive toxicity values. No other hazards were identified for further consideration in the derivation of reference values.

Human studies are preferred over animal studies when quantitative measures of exposure are reported and the effects are determined to be associated with exposure. No human occupational or epidemiological studies of oral exposure to tert-butanol, however, are available.

Animal studies were evaluated to determine which studies provided the most relevant routes and durations of exposure, and multiple exposure levels covering a broad range were used to provide information about the shape of the dose-response curve. The evidence base for tert-butanol includes both chronic and subchronic studies showing effects in the kidney that are suitable for deriving reference values.

#### Kidney Toxicity

EPA identified kidney effects as a potential human hazard of tert-butanol-induced toxicity based on findings in female rats (summarized in Section 1.3.1). Kidney toxicity was observed across multiple chronic, subchronic, and short-term studies following oral and inhalation exposure. Kidney effects, such as suppurative inflammation and transitional epithelial hyperplasia, observed after chronic exposure could influence the ability of the kidney to filter waste. Exacerbated nephropathy also would affect kidney function. Observed changes in kidney weight also could indicate toxic effects in the kidney. For the oral tert-butanol evidence base, several studies that evaluated these kidney effects are available. Huntingdon Life Sciences (2004) conducted a reproductive study in Sprague-Dawley rats that was of shorter duration; the study reported changes in kidney weight but did not examine changes in histopathology. National Toxicology Program (NTP) conducted a 2-year drinking water study (NTP, 1995) in F344 rats that evaluated multiple doses in both males and females and reported on all three endpoints highlighted above. NTP (1995) was identified as the study most suitable for dose-response assessment considering the study duration, comprehensive reporting of outcomes, and multiple doses tested.

In the NTP (1995) 2-year drinking water study, female F344 rats were exposed to approximate doses of 0, 180, 330, or 650 mg/kg-day. Reduced body weights and survival were observed and reflected in some of the effects. Kidney effects, including changes in organ weight, histopathology, or both, were observed in both sexes of rats after 13 weeks, 15 months, and 2 years of treatment (NTP, 1995). Because the kidney effects in male rats are complicated by alpha 2u-globulin, male kidney effects are not considered in developing toxicity values. Specific endpoints in female rats chosen for dose-response analysis were absolute kidney weight, kidney suppurative inflammation, kidney transitional epithelial hyperplasia, and increases in severity of nephropathy. For absolute kidney weight, data from 15-month duration were selected as described in Section 1.2.1; for the other endpoints, data at the longest duration of 2 years were selected.

### 2.1.2 Methods of Analysis

No biologically based dose-response models are available for tert-butanol. In this situation, EPA evaluates a range of dose-response models thought to be consistent with underlying biological processes to determine how best to empirically model the dose-response relationship in the range of the observed data. The models in EPA’s Benchmark Dose Software (BMDS) were applied. Consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012a), the benchmark dose (BMD) and the BMDL are estimated using a benchmark response (BMR) to represent a minimal, biologically significant level of change. In the absence of information regarding the level of change considered biologically significant, a BMR of 1 standard deviation from the control mean for continuous data or a BMR of 10% extra risk for dichotomous data is used to estimate the BMD and BMDL and to facilitate a consistent basis of comparison across endpoints, studies, and assessments. Endpoint-specific BMRs, where feasible, are described further below. When modeling was feasible, the estimated BMDLs were used as points of departure (PODs); the PODs are summarized in Table 2-1. Details including the modeling output and graphical results for the model selected for each endpoint are presented in Appendix C of the Supplemental Information to this Toxicological Review. When modeling was not feasible, the study NOAEL or LOAEL was used as the POD.

Kidney weights were analyzed as absolute weights rather than weights relative to body weight. In general, both absolute and relative kidney-weight data are considered appropriate endpoints for analysis (Bailey et al., 2004). In the NTP (1995) 2-year drinking water study, body weight in exposed animals noticeably decreased relative to controls at the 15-month interim sacrifice, but this decrease in body weight disproportionately influenced the measure of relative kidney weight, resulting in exaggerated kidney-weight changes. Because there was greater confidence in the absolute kidney-weight measure, it was considered more appropriate for dose-response analysis, and changes in relative kidney weights were not analyzed. A 10% relative change from control was used as a BMR for absolute kidney weight, analogous to a 10% change in body weight as an indicator of toxicity. A BMR of 10% extra risk was considered appropriate for the quantal data on incidences of kidney suppurative inflammation and kidney transitional epithelial hyperplasia. Dose-response modeling was not conducted on the increases in severity of nephropathy due to uncertainty regarding BMR selection. That is, it was not clear what critical values, including BMR type as well as values, to use for a common, high background outcome with severity levels as high as moderate even in controls. EPA relied on the interpretation NTP provided (NTP, 1995) and identified the lowest dose, associated with a statistically significantly elevated average severity score, as a LOAEL. Human equivalent doses (HEDs) for oral exposures were derived from the PODs according to the hierarchy of approaches outlined in EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011). The preferred approach is physiologically based pharmacokinetic (PBPK) modeling. Other approaches include using chemical-specific information in the absence of a complete PBPK model. As discussed in Appendix B of the Supplemental Information, human PBPK models for inhalation of ethyl tert-butyl ether (ETBE) or inhalation and dermal exposure to methyl tert-butyl ether (MTBE) have been published, which include tert-butanol submodels. A validated human PBPK model for tert-butanol, however, is not available for extrapolating doses from animals to humans. In lieu of either chemical-specific models or data to inform the derivation of human equivalent oral exposures, body-weight scaling to the ¾ power (BW^3/4^) is applied to extrapolate toxicologically equivalent doses of orally administered agents from adult laboratory animals to adult humans for the purpose of deriving an RfD.

Consistent with EPA guidance (U.S. EPA, 2011), the PODs estimated based on effects in adult animals were converted to HEDs employing a standard dosimetric adjustment factor (DAF) derived as follows:

DAF = (BW_a^1 / 4^_ ÷ BW_h^1 / 4^_) , where BW_a_ = animal body weight BW_h_ = human body weight (2-1)

Using a standard BW_a_ of 0.25 kg for rats and a BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF is 0.24 for rats. Applying this DAF to the POD identified for effects in adult rats yields a POD_HED_ as follows (see Table 2-1):

POD_HED_ = Laboratory animal dose ( mg / kg − day ) × DAF (2-2)

Table 2-1 summarizes all PODs and the sequence of calculations leading to the derivation of a human equivalent POD for each endpoint discussed above.

Table 2-1 Summary of derivations of points of departure following oral exposure for up to 2 years

Endpoint and reference | Species/sex | Model^a^ | BMR | BMD (mg/kg-d) | BMDL (mg/kg-d) | POD_ADJ_^b^ (mg/kg-d) | POD_HED_^c^ (mg/kg-d)
Kidney
Increased absolute kidney weight at 15 mo; NTP (1995) | Rat/F | Exponential (M4) (constant variance) | 10% | 164 | 91 | 91 | 22
Kidney inflammation (suppurative); NTP (1995) | Rat/F | Log-Probit | 10% | 254 | 200 | 200 | 48
Kidney transitional epithelial hyperplasia; NTP (1995) | Rat/F | Multistage (3 degree) | 10% | 412 | 339 | 339 | 81.4
Increases in severity of nephropathy; NTP (1995) | Rat/F | NA | NA | NA | NA | 180^d^ | 43.2

ADJ = adjusted; BMR = benchmark response; HED = human equivalent dose; NA = not applicable.

a For modeling details, see Appendix C in Supplemental Information.

b For studies in which animals were not dosed daily, EPA would adjust administered doses to calculate the time-weighted average daily doses prior to BMD modeling. This adjustment was not required for the NTP (1995) study.

c HED PODs were calculated using BW^3/4^ scaling (U.S. EPA, 2011).

d POD calculated from the LOAEL (lowest dose tested had a significant increase in severity).

### 2.1.3 Derivation of Candidate Values

Consistent with EPA’s A Review of the Reference Dose and Reference Concentration Processes [U.S. EPA (2002); see Section 4.4.5], also described in the Preamble, five possible areas of uncertainty and variability were considered when determining the application of UF values to the PODs presented in Table 2-1. An explanation follows.

An intraspecies uncertainty factor, UF_H_, of 10 was applied to all PODs to account for potential differences in toxicokinetics and toxicodynamics in the absence of information on the variability of response in the human population following oral exposure to tert-butanol (U.S. EPA, 2002).

An interspecies uncertainty factor, UF_A_, of 3 (10^0.5^ = 3.16, rounded to 3) was applied to all PODs because BW^3/4^ scaling was used to extrapolate oral doses from laboratory animals to humans. Although BW^3/4^ scaling addresses some aspects of cross-species extrapolation of toxicokinetic and toxicodynamic processes, some residual uncertainty in the extrapolation remains. In the absence of chemical-specific data to quantify this uncertainty, EPA’s BW^3/4^ guidance (U.S. EPA, 2011) recommends use of an uncertainty factor of 3.

A subchronic-to-chronic uncertainty factor, UF_s_, of 1 was applied to all PODs because all endpoints were observed following chronic exposure.

A LOAEL-to-NOAEL uncertainty factor, UF_L_, of 1 was applied to most PODs derived because the current approach is to address this factor as one of the considerations in selecting a BMR for benchmark dose modeling. In this case, BMRs of a 10% relative change in absolute kidney weight, a 10% extra risk of kidney suppurative inflammation, and a 10% extra risk of transitional cell hyperplasia were selected, assuming they represent minimal biologically significant response levels. A LOAEL-to-NOAEL uncertainty factor of 3 was applied to the increases in severity of nephropathy. Although a LOAEL was used to derive the POD, the severity of 1.9 was only slightly higher than the control value of 1.6, indicating that the LOAEL was close to the result in controls.

A database uncertainty factor, UF_D_, of 1 was applied to all PODs. The tert-butanol oral toxicity evidence base includes chronic and subchronic toxicity studies in rats and mice (Acharya et al., 1997; Acharya et al., 1995; NTP, 1995) and developmental toxicity studies in rats and mice (Huntingdon Life Sciences, 2004; Faulkner et al., 1989; Daniel and Evans, 1982). In the developmental studies, no effects were observed at exposure levels below 1,000 mg/kg-day, and effects observed at ≥1,000 mg/kg-day were accompanied by evidence of maternal toxicity. These exposure levels are much higher than the PODs for kidney effects, suggesting any selective developmental toxicity is not as sensitive an endpoint as kidney effects. No immunotoxicity or multigenerational reproductive studies are available for tert-butanol. Studies on ETBE, which is rapidly metabolized to systemically available tert-butanol, are informative for considering the gaps in the tert-butanol oral evidence base. The evidence base for ETBE does not indicate immunotoxicity (Banton et al., 2011; Li et al., 2011), suggesting immune system effects would not be a sensitive target for tert-butanol. No adverse effects were reported in one- and two-generation reproductive/developmental studies on ETBE (Gaoua, 2004a, b), indicating that reproductive/developmental effects would not be a sensitive target for tert-butanol. Additionally, a one-generation, reproductive toxicity study in rats from a Toxic Substances Control Act submission (Huntingdon Life Sciences, 2004) is available for tert-butanol. This study did not observe reproductive effects. Although the oral toxicity evidence base for tert-butanol has some gaps, the available data on tert-butanol, informed by the data on ETBE, do not suggest that additional studies would lead to identification of a more sensitive endpoint or a lower POD. Therefore, a UF_D_ of 1 was applied.

Table 2-2 is a continuation of Table 2-1 and summarizes the application of UF values to each POD to derive a candidate value for each data set, preliminary to the derivation of the organ/system-specific RfDs. These candidate values are considered individually in selecting a representative oral reference value for a specific hazard and subsequent overall RfD for tert-butanol. Figure 2-1 presents graphically the candidate values, UF values, and POD_HED_ values, with each bar corresponding to one data set described in Table 2-1 and Table 2-2.

Table 2-2 Effects and corresponding derivation of candidate values

Endpoint and reference | POD_HED_ (mg/kg-d) | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (mg/kg-d)
Kidney
Increased absolute kidney weight; female rat at 15 mo NTP (1995) | 22 | BMDL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 7 × 10^−1^
Kidney inflammation (suppurative); female rat at 2 yr NTP (1995) | 48 | BMDL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 2 × 10^0^
Kidney transitional epithelial hyperplasia; female rat at 2 yr NTP (1995) | 81 | BMDL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 3 × 10^0^
Increases in severity of nephropathy; female rat at 2 yr NTP (1995) | 43.2 | LOAEL | 3 | 10 | 3 | 1 | 1 | 100 | 4 × 10^−1^

Figure 2-1 Candidate values with corresponding POD and composite uncertainty factor (UF)

Each bar corresponds to one data set described in Table 2-1 and Table 2-2

### 2.1.4 Derivation of Organ/System-Specific Reference Doses

Table 2-3 distills the candidate values from Table 2-2 into a single value for each organ or system. Organ- or system-specific RfDs are useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site.

#### Kidney Toxicity

To estimate an exposure level below which kidney toxicity from tert-butanol exposure is not expected to occur, the RfD for greater increases in severity of nephropathy in female rats (4 × 10^−1^ mg/kg-day) was selected as the kidney-specific reference dose for tert-butanol. The database for tert-butanol is relatively small ;therefore, a limited number of endpoints were considered for kidney toxicity including absolute kidney weight, suppurative inflammation, transition epithelial hyperplasia, and increased severity of nephropathy. Increased severity of nephropathy is considered a specific marker of kidney function and more sensitive than the relatively nonspecific endpoint of absolute kidney-weight changes, and more sensitive than the endpoints of inflammation and transitional epithelial hyperplasia. Confidence in this kidney-specific RfD is medium, in part, due to the scientific disagreement on the human relevance of CPN which remains unresolved. The POD for increases in severity of nephropathy is within 2-fold of other endpoints and is based on a LOAEL Although the use of a LOAEL adds some uncertainty, only an UF_L_ of 3 was applied based on the magnitude of change observed at the LOAEL All of the candidate values are derived from a well-conducted, long-term study involving a sufficient number of animals per group, including both sexes, and assessing a wide range of kidney endpoints.

Table 2-3 Organ/system-specific oral reference doses (RfDs) and overall RfD for tert-butanol

Effect | Basis | RfD (mg/kg-d) | Study exposure description | Confidence
Kidney | Increases in severity of nephropathy (NTP, 1995) | 4 × 10^−1^ | Chronic | Medium
Overall RfD | Kidney | 4 × 10^−1^ | Chronic | Medium

### 2.1.5 Selection of the Overall Reference Dose

For tert-butanol, only kidney effects were identified as a hazard and carried forward for dose-response analysis; thus, only one organ/system-specific reference dose was derived. Therefore, the kidney-specific RfD of 4 × 10^−1^ mg/kg-day is the overall RfD for tert-butanol. This value is based on greater increases in severity of nephropathy in female rats exposed to tert-butanol.

The overall reference dose is derived to be protective of all types of effects for a given duration of exposure and is intended to protect the population as a whole, including potentially susceptible subgroups (U.S. EPA, 2002). Decisions concerning averaging exposures over time for comparison with the RfD should consider the types of toxicological effects and specific lifestages of concern. Fluctuations in exposure levels that result in elevated exposures during these lifestages could lead to an appreciable risk, even if average levels over the full exposure duration were less than or equal to the RfD. In the case of tert-butanol, the potential exists for early lifestage susceptibility to tert-butanol exposure, as discussed in Section 1.3.3.

### 2.1.6 Confidence Statement

A confidence level of high, medium, or low is assigned to the study used to derive the RfD, the overall evidence base, and the RfD, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). Confidence in the principal study (NTP, 1995) is high. This study was well conducted, complied with Food and Drug Administration (FDA) Good Laboratory Practice (GLP) regulations, involved 50 animals per dose group (including both sexes), and assessed a wide range of tissues and endpoints. The toxicity evidence base for tert-butanol has some gaps such as a lack of human studies and limited reproductive/development toxicity data, despite the inclusion of data on ETBE, a parent compound of tert-butanol. Therefore, the confidence in the RfD is medium based on the high confidence in the principal study and medium confidence in the evidence base.

### 2.1.7 Previous Integrated Risk Information System (IRIS) Assessment

No previous oral assessment for tert-butanol is available in IRIS.

## 2.2 INHALATION REFERENCE CONCENTRATION FOR EFFECTS OTHER THAN CANCER

The inhalation reference concentration (RfC; expressed in units of mg/m^3^) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a NOAEL, LOAEL, or the benchmark concentration lower confidence level (BMCL), with UF values generally applied to reflect limitations of the data used.

### 2.2.1 Identification of Studies and Effects for Dose-Response Analysis

As for oral exposure, EPA identified kidney effects as a potential human hazard of tert-butanol inhalation exposure (summarized in Section 1.3.1). No chronic inhalation study for tert-butanol is available; only one 13-week study in rats and mice is available (NTP, 1997). A rat PBPK model was available for both oral and inhalation exposure, which was suitable for a route-to-route (RTR) extrapolation (Borghoff et al., 2016). As a result, rat studies from both routes of exposure were considered for dose-response analysis.

The evidence base for tert-butanol includes oral and inhalation studies and data sets that are potentially suitable for use in deriving inhalation reference values. Specifically, effects associated with tert-butanol exposure in animals include observations of organ weight and histological changes in the kidney in chronic and subchronic studies in female rats.

#### Kidney Toxicity

EPA identified kidney effects as a potential human hazard of tert-butanol exposure based on findings of organ-weight changes and histopathology primarily in male rats; however, the kidney effects in male rats are complicated by the presence of alpha 2u-globulin. Therefore, kidney effects in male rats are not considered. The kidney findings were observed across multiple chronic, subchronic, and short-term studies following oral and inhalation exposure. The subchronic NTP (1997) inhalation study is the only route-specific study available, and was carried forward for further analysis. For oral studies considered for RTR extrapolation, see Section 2.1.1 for a summary of considerations for selecting oral studies for dose-response analysis. Overall, the NTP 2-year drinking water study (NTP, 1995) was identified as the study most suitable for dose-response assessment, given the study duration, comprehensive reporting of outcomes, use of multiple species tested, multiple doses tested, and availability of a PBPK model for RTR extrapolation. This study was discussed previously in Section 2.1.1 as part of the derivation of the oral reference dose, so it is not reviewed here again. The NTP (1997) subchronic inhalation study shares many strengths with the 2-year drinking water study (NTP, 1995) and is described in more detail below.

NTP (1997) was a well-designed subchronic study that evaluated the effect of tert-butanol exposure on multiple species at multiple inhalation doses. Relative kidney weights were elevated in females at 6,368 mg/m^3^. Few endpoints were available for consideration in the subchronic inhalation study, but changes in kidney weights also were observed in the oral studies, such as the NTP (1995) 2-year drinking water study.

### 2.2.2 Methods of Analysis

No biologically based dose-response models are available for tert-butanol. In this situation, EPA evaluates a range of dose-response models considered consistent with underlying biological processes to determine how best to model the dose-response relationship empirically in the range of the observed data. Consistent with this approach, all models available in EPA’s BMDS were evaluated. Consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012a), the benchmark dose or concentration (BMD/C) and the 95% lower confidence limit on the BMD/C (BMD/CL) were estimated using a BMR of 10% change from the control mean for absolute kidney-weight changes (as described in Section 2.1.2). As noted in Section 2.1.2, a BMR of 10% extra risk was considered appropriate for the quantal data on incidences of kidney suppurative inflammation and kidney transitional epithelial hyperplasia. The estimated BMD/CLs were used as PODs. When dose-response modeling was not feasible, NOAELs or LOAELs were identified and summarized in Table 2-4. Further details, including the modeling output and graphical results for the best-fit model for each endpoint, are found in Appendix C of the Supplemental Information.

#### Points of Departure (PODs) from Inhalation Studies

Because the RfC is applicable to a continuous lifetime human exposure but derived from animal studies featuring intermittent exposure, EPA guidance (U.S. EPA, 1994) provides mechanisms for (1) adjusting experimental exposure concentrations to a value reflecting continuous exposure duration (ADJ) and (2) determining a human equivalent concentration (HEC) from the animal exposure data. The former employs an inverse concentration-time relationship to derive a health-protective duration adjustment to time weight the intermittent exposures used in the studies. The modeled BMCL from the inhalation study (NTP, 1997) was adjusted to reflect a continuous exposure by multiplying it by (6 hours per day) ÷ (24 hours per day) and (5 days per week) ÷ (7 days per week) as follows:

BMCL_ADJ_ = BMCL (mg / m^3^) × ( 6 ÷ 24 ) × ( 5 ÷ 7 ) = BMCL (mg / m^3^) × ( 0.1786 ) (2-3)

The RfC methodology provides a mechanism for deriving an HEC from the duration-adjusted POD (BMCL_ADJ_) determined from the animal data. The approach takes into account the extrarespiratory nature of the toxicological responses and accommodates species differences by considering blood:air partition coefficients for tert-butanol in the laboratory animal (rat or mouse) and humans. According to the RfC guidelines (U.S. EPA, 1994), tert-butanol is a Category 3 gas because extrarespiratory effects were observed. Kaneko et al. (2000) measured an animal blood:gas partition coefficient (Hb/g-A) of 531 ± 102 for tert-butanol in male Wistar rats, while Borghoff et al. (1996) measured a value of 481 ± 29 in male F344 rats. A human blood:gas partition coefficient (Hb/g-H) of 462 was reported for tert-butanol (Nihlén et al., 1995). The calculation Hb/g-A ÷ Hb/g-H was used to calculate a blood:gas partition coefficient ratio to apply to the delivered concentration. Because F344 rats were used in the study, the blood:gas partition coefficient for F344 rats was used. Thus, the calculation was 481 ÷ 462 = 1.04. A ratio of 1.04 was used to calculate the HEC. This allowed a BMCL_HEC_ to be derived as follows:

BMCL_HEC_ = BMCL_ADJ_ (mg / m^3^) × ( interspecies conversion ) = BMCL_ADJ_ (mg / m^3^) × ( 481 ÷ 462 ) = BMCL_ADJ_ (mg / m^3^) × ( 1.04 ) (2-4)

Table 2-4 summarizes the sequence of calculations leading to the derivation of a human equivalent POD for each inhalation data set discussed above.

Table 2-4 Summary of derivation of PODs following inhalation exposure

Endpoint and reference | Species/Sex | Model^a^ | BMR | BMC^b^ (mg/m^3^) | BMCL^b^ (mg/m^3^) | POD_ADJ_^b^ (mg/m^3^) | POD_HEC_^c^ (mg/m^3^)
Kidney
Increased absolute kidney weight at 13 wk; NTP (1997) | Rat (F344)/female | No model selected^d^ | 10% | – | – | 1,137 | 1,137

BMC = benchmark concentration.

a For modeling details, see Appendix C in Supplemental Information.

b BMCs, BMCLs, and PODs were adjusted for continuous daily exposure by multiplying by (h exposed per d/24 h) × (d exposed per wk/7 d).

c POD_HEC_ calculated by adjusting the POD_ADJ_ by the DAF (= 1.0, rounded from 1.04) for a Category 3 gas (U.S. EPA, 1994).

d BMD modeling failed to calculate a BMD value successfully (see Appendix C); POD calculated from NOAEL of 6,368 mg/m^3^.

#### Points of Departure (PODs) from Oral Studies—Use of Physiologically Based Pharmacokinetic (PBPK) Model for Route-to-Route (RTR) Extrapolation

A PBPK model for tert-butanol in rats has been modified, as described in Appendix B of the Supplemental Information. A critical decision in the RTR extrapolation is selection of the internal dose metric that establishes “equivalent” oral and inhalation exposures. For tert-butanol-induced kidney effects, the two options are the concentration of tert-butanol in blood and the rate of tert-butanol metabolism. Note that using the kidney concentration of tert-butanol will lead to the same route-to-route extrapolation relationship as tert-butanol in blood because the distribution from blood to kidney is independent of route. Data are not available to suggest that metabolites of tert-butanol mediate its renal toxicity. Without evidence suggesting otherwise, tert-butanol is assumed to be the active toxicological agent. Moreover, since extrapolation is within the same species, use of the rate of metabolism as the metric (the alternate possibility) will only result in a different value to the extent that there is nonlinearity (saturation) in the metabolism versus concentration, and this differs for oral versus inhalation exposure. For example, for the internal dose of 61.9 mg/L average blood concentration (C_avg_, associated with a BMDL of 200 mg/kg-day oral exposure), the corresponding average rate of metabolism is 0.83 mg/h (M_avg_). If using C_avg_ as the metric, the corresponding continuous inhalation concentration for the rat is 523.7 mg/m^3^. If using M_avg_ as the metric, the corresponding continuous rat inhalation concentration is 439.9 mg/m, only 16% lower. Hence, from a practical standpoint the choice between these two possible metrics has little impact. On the other hand, the use of metabolic rate has a higher degree of qualitative uncertainty in that a submodel does not exist for the key metabolite(s) that can be used to estimate its (their) internal concentration under different scenarios. The rate of metabolism is only inferred by observing the rate of tert-butanol clearance; tert-butanol blood concentrations after various exposures have been measured directly. Therefore, the concentration of tert-butanol in blood was selected as the dose metric.

Using the PBPK model (U.S EPA, 2016), RTR extrapolation of the oral BMDLs or LOAEL to derive inhalation PODs was therefore performed as follows. First, the internal dose in the rat at each oral BMDL or LOAEL (assuming oral exposure by a circadian drinking water pattern) was estimated using the PBPK model to derive an “internal dose BMDL or LOAEL.” More specifically, for noncontinuous exposures, the PBPK model was run for a number of days or weeks such that the predicted time course of tert-butanol in blood did not change with further days or weeks simulated (e.g., until blood concentration during the 2nd-to-last day of exposure was predicted to be the same as the last day of exposure). This state is referred to as “periodicity.” The average blood concentration of tert-butanol was calculated during the final periodic exposure for oral exposure at the BMDL for a given endpoint. For uniformity, all model scripts calculated the average from episodic exposures on the basis of the final week of exposure, regardless of whether exposure is daily or 5 times per week, because either exposure profile will be fully captured by averaging a 1-week time period.

For continuous inhalation exposures (24 hours/day, 7 days/week), the steady-state blood concentration at the end of a simulation is equal to the average blood concentration for the last week. Therefore, the continuous inhalation exposure equivalent to an oral BMDL was identified by using the PBPK model to identify the inhalation concentration for which the final (steady-state) blood concentration was equal to the average blood concentration for the last week of oral exposure at the oral BMDL. The resulting POD then was converted to a POD_HEC_ using the methodology previously described in the section, PODs from Inhalation Studies:

POD_HEC_ = POD (mg / m^3^) × ( interspecies conversion ) = POD (mg / m^3^) × ( 481 ÷ 462 ) = POD (mg / m^3^) × ( 1.04 ) (2-5)

Table 2-5 summarizes the sequence of calculations leading to the derivation of a human equivalent inhalation POD from each oral data set discussed above.

Table 2-5 Summary of inhalation points of departure derived from route-to-route extrapolation from oral exposures

Endpoint and reference | Species/sex | BMR | BMDL (mg/kg-d) | Internal dose^a^ (mg/L) | Equivalent POD^b^ (mg/m^3^) | Equivalent POD_HEC_^c^ (mg/m^3^)
Kidney
Mean absolute kidney weight at 15 mo NTP (1995) | Rat/female | 10% | 91 | 21.5 | 238.9 | 248
Kidney inflammation (suppurative) at 2 yr NTP (1995) | Rat/female | 10% | 200 | 61.9 | 523.7 | 545
Kidney transitional epithelial hyperplasia at 2 yr NTP (1995) | Rat/female | 10% | 339 | 127 | 883.9 | 919
| Species/sex | POD (LOAEL; mg/kg-d) | | Internal dose^a^ (mg/L) | Equivalent POD^b^ (mg/m^3^) | Equivalent POD_HEC_^c^ (mg/m^3^)
Increases in severity of nephropathy at 2 yr NTP (1995) | Rat/female | 180 | | 53.6 | 471.8 | 491

a Average rodent blood concentration of tert-butanol under circadian drinking water ingestion at the BMDL.

b Continuous inhalation equivalent concentration that leads to the same average blood concentration of tert-butanol as circadian drinking water ingestion at the BMDL in the rat.

c Continuous inhalation human equivalent concentration that leads to the same average blood concentration of tert-butanol as continuous oral exposure at the BMDL. Calculated as the rodent POD × 1.04.

To our knowledge, a meta-analysis of the accuracy of RTR extrapolation using PBPK models has not been conducted. Ideally one would evaluate results for multiple chemicals, for which a PBPK model and both oral and inhalation toxicity studies have been conducted, to determine the accuracy of RTR extrapolation by comparing a predicted point of departure (e.g., BMD) with actual data for the alternate route. For chloroform, use of a PBPK model has been shown to be successful at correlating a response with internal dose irrespective of exposure route, including combined inhalation and oral exposures (Sasso et al., 2013). Conversely, prenatal exposure of rats to inhaled ethanol did not result in the degree of teratological effects expected, even though the internal dose achieved (blood ethanol concentration [BEC]) was in the range associated with those effects when ethanol is orally ingested (Oshiro et al., 2014). In the latter case, although a PBPK model could successfully predict the inhalation concentration of ethanol that yields a similar BEC to oral exposure, the RTR extrapolation effectively failed because the same level of effect did not occur. Thus, even for a well-studied compound like ethanol, the internal dose metric presumed to be correct may in fact be inadequate for accurate extrapolation. Together these results indicate both promise and uncertainty in RTR extrapolation.

Despite the uncertainty, a chemical must enter the body and be distributed through the blood to affect internal tissues. Therefore, the toxicological activity must be related to blood concentration, although it may not be exactly predicted by a particular metric. In the case of tert-butanol, there is toxicological uncertainty because a chronic inhalation bioassay has not been conducted. Thus, one must make a judgment as to whether it is more uncertain to extrapolate from a subchronic inhalation bioassay or a chronic oral bioassay. Because a quantitative analysis of RTR extrapolation across chemicals has not been conducted, it is not possible to quantitatively compare the uncertainty of these two options. The EPA has assumed in this assessment that extrapolation across study duration is more uncertain than extrapolation across exposure routes, given that toxicity must be related to the concentration of tert-butanol in the blood.

### 2.2.3 Derivation of Candidate Values

In EPA’s A Review of the Reference Dose and Reference Concentration Processes [U.S. EPA (2002); see Section 4.4.5], also described in the Preamble, five possible areas of uncertainty and variability were considered. Several PODs for the candidate inhalation values were derived using a RTR extrapolation from the PODs estimated from the chronic oral toxicity study in rats (NTP, 1995) in deriving the RfD (see Section 2.1). Except for the subchronic inhalation study (NTP, 1997), the UF values selected and applied to PODs derived from the chronic oral study (NTP, 1995) for RTR extrapolation are the same as those for the RfD for tert-butanol (see Section 2.1.3). The model used to perform this RTR extrapolation is a well-characterized model considered appropriate for the purposes of this assessment.

For the PODs derived from the subchronic inhalation study (NTP, 1997), a UF_S_ of 10 was applied to account for extrapolation from subchronic-to-chronic duration.

Table 2-6 is a continuation of Table 2-4 and Table 2-5, and summarizes the application of UF values to each POD to derive a candidate value for each data set. The candidate values presented in the table below are preliminary to the derivation of the organ/system-specific reference values. These candidate values are considered individually in selecting a representative reference value for inhalation for a specific hazard and subsequent overall RfC for tert-butanol.

Figure 2-2 presents graphically the candidate values, UF values, and POD_HEC_ values, with each bar corresponding to one data set described in Table 2-4, Table 2-5, and Table 2-6.

Table 2-6 Effects and corresponding derivation of candidate values

Endpoint (sex and species) and reference | POD_HEC_ (mg/m^3^) | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (mg/m^3^)
Kidney
Increased absolute kidney weight at 13 wk; female rat; NTP (1997) | 1,137 | NOAEL | 3 | 10 | 1 | 10 | 1 | 300 | 4 × 10^0^
Increased absolute kidney weight at 15 mo; female rat; NTP (1995) | 248 | BMCL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 8 × 10^0a^
Kidney inflammation (suppurative); female rat at 2 yr; NTP (1995) | 546 | BMCL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 2 × 10^1a^
Kidney transitional epithelial hyperplasia; female rat at 2 yr; NTP (1995) | 920 | BMCL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 3 × 10^1a^
Increases in severity of nephropathy; female rat at 2 yr; NTP (1995) | 491 | LOAEL | 3 | 10 | 3 | 1 | 1 | 100 | 5 × 10^0a^

a These candidate values are derived using RTR extrapolated PODs based on NTP’s chronic drinking water study.

Figure 2-2 Candidate inhalation reference concentration (RfC) values with corresponding point of departure (POD) and composite uncertainty factor (UF)

### 2.2.4 Derivation of Organ/System-Specific Reference Concentrations

Table 2-7 distills the candidate values from Table 2-6 into a single value for the kidney. Organ/system-specific reference values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site.

#### Kidney Toxicity

For the derivation of candidate values, whether PODs from the subchronic inhalation study of NTP (1997) would provide a better basis than the RTR extrapolated PODs based on the chronic oral study of NTP (1995) must be considered. To estimate an exposure level below which kidney toxicity from tert-butanol exposure is not expected to occur, the RfC for increases in severity of nephropathy in female rats (5 × 10^0^ mg/m^3^) was selected as the kidney-specific RfC for tert-butanol, consistent with the selection of the kidney-specific RfD (see Section 2.1.4). Justification for the selection of increased severity of nephropathy is discussed in Section 2.1.4. Similar to the RfD confidence in this kidney-specific RfC is medium.

Table 2-7 Organ/system-specific inhalation reference concentrations (RfCs) and overall RfC for tert-butanol

Effect | Basis | RfC (mg/m^3^)^a^ | Study exposure description | Confidence
Kidney | Increases in severity of nephropathy (NTP, 1995) | 5 × 10^0^ | Chronic | Medium
Overall RfC | Kidney | 5 × 10^0^ | Chronic | Medium

a Derived from oral study, by RTR extrapolation.

### 2.2.5 Selection of the Overall Reference Concentration

For tert-butanol, kidney effects were identified as the primary hazard; thus, a single organ/system-specific RfC was derived. The kidney-specific RfC of 5 × 10^0^ mg/m^3^ is selected as the overall RfC, representing an estimated exposure level below which deleterious effects from tert-butanol exposure are not expected to occur.

The overall RfC is derived to be protective of all types of effects for a given duration of exposure and is intended to protect the population as a whole, including potentially susceptible subgroups (U.S. EPA, 2002). Decisions concerning averaging exposures over time for comparison with the RfC should consider the types of toxicological effects and specific lifestages of concern. Fluctuations in exposure levels that result in elevated exposures during these lifestages could lead to an appreciable risk, even if average levels over the full exposure duration were less than or equal to the RfC. The potential exists for early lifestage susceptibility to tert-butanol exposure, as discussed in Section 1.3.3.

### 2.2.6 Confidence Statement

A confidence level of high, medium, or low is assigned to the study used to derive the RfC, the overall evidence base, and the RfC itself, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). A PBPK model was used to perform an RTR extrapolation to determine a POD for deriving the RfC from the NTP (1995) oral study and corresponding critical effect. Confidence in the principal study (NTP, 1995) is high. This study was well conducted, complied with FDA GLP regulations, involved 50 animals per group (including both sexes), and assessed a wide range of tissues and endpoints. Although the toxicity evidence base for tert-butanol contains some gaps, these areas are partially informed by the data on ETBE, a parent compound of tert-butanol. Therefore, the confidence in the evidence base is medium. Reflecting high confidence in the principal study, medium confidence in the evidence base, and minimal uncertainty surrounding the application of the modified PBPK model for the purposes of an RTR extrapolation, the overall confidence in the RfC for tert-butanol is medium.

### 2.2.7 Previous Integrated Risk Information System (IRIS) Assessment

No previous inhalation assessment for tert-butanol is available in IRIS.

### 2.2.8 Uncertainties in the Derivation of the Reference Dose and Reference Concentration

The following discussion identifies uncertainties associated with the RfD and RfC for tert-butanol. To derive the RfD, the UF approach (U.S. EPA, 2000, 1994) was applied to a POD based on kidney toxicity in rats treated chronically. UF values were applied to the POD to account for extrapolating from an animal bioassay to human exposure, and the likely existence of a diverse human population of varying susceptibilities. These extrapolations are carried out with default approaches, given the lack of data to inform individual steps. To derive the RfC, this same approach was applied, but a PBPK model was used to extrapolate from oral to inhalation exposure.

The evidence base for tert-butanol contains no human data on adverse health effects from subchronic or chronic exposure, and the PODs were calculated from data on the effects of tert-butanol reported by studies in rats. The evidence base for tert-butanol exposure includes one lifetime bioassay, several reproductive/developmental studies, and several subchronic oral studies.

Although the evidence base is adequate for reference value derivation, uncertainty is associated with the lack of a comprehensive multigeneration reproductive toxicity study. Additionally, only subchronic and short-term inhalation studies have been conducted, and no chronic inhalation studies are available. Developmental studies identified significant increases in fetal loss, decreases in fetal body weight, and possible increases in skeletal variations in exposed offspring or pups. Effects were not always consistent across exposure routes, however, and maternal toxicity was present whenever developmental effects were observed.

The toxicokinetic and toxicodynamic differences for tert-butanol between the animal species in which the POD was derived and humans are unknown. The tert-butanol evidence base lacks an adequate model that would inform potential interspecies differences (a limited data set exists for tert-butanol appearing as a metabolite from ETBE exposure in humans, but none for direct exposure to tert-butanol). Generally, rats seemed more susceptible than mice, and males more susceptible than females to tert-butanol toxicity. The underlying mechanistic basis of these apparent differences, however, is not understood. Most importantly, which animal species or sexes might be more comparable to humans is unknown.

Another uncertainty to consider relates to the mode-of-action (MOA) analysis conducted for the kidney effects. The assessment concluded that tert-butanol is a weak inducer of alpha 2u-globulin, which is operative in male kidney tumors; therefore, noncancer effects related to alpha 2u-globulin were considered not relevant for hazard identification and, therefore, not suitable for dose-response consideration. If this conclusion were incorrect and the noncancer effects characterized in this assessment as being related to alpha 2u-globulin were relevant to humans, the RfD and RfC values could underestimate toxicity. The assessment also used noncancer effects related to CPN in deriving the reference values. If noncancer effects characterized in this assessment as being related to CPN were not relevant to humans, the RfD value (0.4 mg/kg-day) could slightly overestimate toxicity compared with an alternative endpoint (increased absolute kidney weight [0.7 mg/kg-day]), while the RfC value would be similar (5 mg/m^3^ compared with 4 mg/m^3^).

## 2.3 ORAL SLOPE FACTOR FOR CANCER

The oral slope factor (OSF) is a plausible upper bound on the estimate of risk per mg/kg-day of oral exposure. The OSF can be multiplied by an estimate of lifetime exposure (in mg/kg-day) to estimate the lifetime cancer risk.

### 2.3.1 Analysis of Carcinogenicity Data

As noted in Section 1.3.2, there is suggestive evidence of carcinogenic potential for tert-butanol. The Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005b) state:

When there is suggestive evidence, the Agency generally would not attempt a dose-response assessment, as the nature of the data generally would not support one; however, when the evidence includes a well-conducted study, quantitative analysis may be useful for some purposes, for example, providing a sense of the magnitude and uncertainty of potential risks, ranking potential hazards, or setting research priorities. In each case, the rationale for the quantitative analysis is explained, considering the uncertainty in the data and the suggestive nature of the weight of evidence. These analyses generally would not be considered Agency consensus estimates.

No human data relevant to an evaluation of the carcinogenicity of tert-butanol were available. The cancer descriptor was based on the 2-year drinking water study in rats and mice by NTP (1995), which reported renal tumors in male rats and thyroid tumors in both male and female mice. This study was considered suitable for dose-response analysis. It was conducted in accordance with FDA GLP regulations, and all aspects were subjected to retrospective quality assurance audits. The study included histological examinations for tumors in many different tissues, contained three exposure levels and controls, contained adequate numbers of animals per dose group (~50/sex/group), treated animals for up to 2 years, and included detailed reporting of methods and results. Additionally, the renal tumors were reexamined by a Pathology Working Group (Hard et al., 2011).

Dose-related increasing trends in tumors were noted at the following sites:

- Renal tubule adenomas and carcinomas in male rats and
- Thyroid follicular adenomas in female mice and thyroid follicular adenomas and carcinoma in male mice.

These tumors were statistically significantly increased by pairwise comparison (Fisher’s exact test, p ≤ 0.05) and by trend test (Cochran-Armitage trend test, p ≤ 0.05). Based on a mode of action analysis, the alpha 2u-globulin process, in addition to other unknown processes, was concluded to be at least partially responsible for the male rat renal tumors. Because the relative contribution of each process to tumor formation cannot be determined (U.S. EPA, 1991a), the renal tumors in male rats are not considered suitable for quantitative analysis. Conversely, the thyroid tumors in mice are suitable for dose-response analysis and unit risk estimation, as described in Section 1.3.2, and the available data do not demonstrate that the thyroid tumors are the result of excessive toxicity in female mice. The final average body-weight reduction in female mice at the highest dose was 12% (NTP, 1995), but water consumption by exposed females was similar to controls and no overt toxicity was observed. Furthermore, female mice in the high-dose group had higher rates of survival than control animals. The final average body weight reduction in male mice at the highest dose was 5% to 10% (NTP, 1995) and water consumption by exposed males was similar to controls, but survival was reduced at the highest dose and the tumor response in male mice was adjusted for early mortality. Considering these data, along with the uncertainty associated with the suggestive nature of the weight of evidence, quantitative analysis of the tumor data may be useful for providing a sense of the magnitude of potential carcinogenic risk from tert-butanol exposure, including worker and consumer exposures. Although this assessment determined that the female mouse thyroid data set is suitable for dose-response modeling and calculation of a quantitative risk estimate, there is increased uncertainty in this risk estimate owing to the suggestive nature of the tumorigenic response (U.S. EPA, 2005a).

### 2.3.2 Dose-Response Analysis—Adjustments and Extrapolations Methods

The EPA Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005b) recommend the method for characterizing and quantifying cancer risk from a chemical be based on what is known about the MOA of the carcinogen and the shape of the cancer dose-response curve. EPA uses a two-step approach that distinguishes analysis of the observed dose-response data from inferences about lower doses (U.S. EPA, 2005b). Within the observed range, the preferred approach is to use modeling to incorporate a wide range of data into the analysis, such as through a biologically based model, if supported by substantial data. Without a biologically based model, as in the case of tert-butanol, a standard model is used for curve fitting the data and estimating a POD. EPA uses the multistage model in IRIS dose-response analyses for cancer (Gehlhaus et al., 2011) because it parallels the multistage carcinogenic process and fits a broad array of dose-response patterns.

The second step, extrapolation to lower exposures from the POD, considers what is known about the modes of action for each effect. As above, a biologically based model is preferred (U.S. EPA, 2005b). Otherwise, linear low-dose extrapolation is recommended if the MOA of carcinogenicity is mutagenic or has not been established (U.S. EPA, 2005b). For tert-butanol, the mode(s) of carcinogenic action for thyroid follicular cell tumors has not been established (see Section 1.3.2). Therefore, linear low-dose extrapolation was used to estimate human carcinogenic risk.

The dose-response modeling used administered dose because a PBPK model to characterize internal dosimetry in mice was not available. For the analysis of thyroid tumors, the incidence data were adjusted to account for the increased mortality in high-dose male mice, relative to the other groups, that reduced the number of mice at risk for developing tumors. The Poly-3 method (Bailer and Portier, 1988) was used to estimate the number at risk of developing tumors, by weighting the length of time each animal was on study (details in Appendix C of the Supplemental Information). This method was not applied to the female mice data because a difference in survival with increasing exposure was not appreciable and only one tumor, in the high-dose group, occurred before study termination.

The data modeled and other details of the modeling are provided in Appendix C. The BMDs and BMDLs recommended for each data set are summarized in Table 2-8. The modeled tert-butanol PODs were scaled to HEDs according to EPA guidance (U.S. EPA, 2011, 2005b). In particular, the BMDL was converted to an HED by assuming that doses in animals and humans are toxicologically equivalent when scaled by BW^3/4^. Standard body weights of 0.025 kg for mice and 70 kg for humans were used (U.S. EPA, 1988). The following formula was used for converting an oral BMDL to oral HED for mouse endpoints:

HED in mg/kg-day = ( BMDL in mg/kg-day ) × ( animal body weight / 70 )^1 / 4^ = ( BMDL in mg/kg-day ) × 0.14 (2-6)

PODs for estimating low-dose risk were identified at doses at the lower end of the observed data, corresponding to 10% extra risk in female mice and 5% extra risk in male mice.

### 2.3.3 Derivation of the Oral Slope Factor

The PODs estimated for each tumor data set are summarized in Table 2-8. The lifetime oral cancer slope factor for humans is defined as the slope of the line from the lower 95% bound on the exposure at the POD to the control response (slope factor = BMR/BMDL_BMR_ = 0.1/BMDL_10_). This slope represents a plausible upper bound on the true population average risk. Using linear extrapolation from the BMDL_10_, human equivalent oral slope factors were derived for male and female mice and are listed in Table 2-8.

The oral slope factor based on the incidence of thyroid follicular cell adenomas in female mice was 5 × 10^−4^ per mg/kg-day. Despite high mortality in high-dose male mice, estimating slope factors using the Poly-3 method was feasible for addressing competing risks. Whether using the full data set (including the only thyroid follicular cell carcinoma observed at the highest dose) or omitting the high-dose group altogether (under the assumption that mortality in this group was too extensive to interpret the results), oral slope factors based on the incidence of thyroid follicular cell adenomas or carcinomas in male mice were similar when rounded to one significant digit (5 × 10^−4^ per mg/kg-day or 6 × 10^−4^ per mg/kg-day, respectively).

The recommended slope factor^11^ for lifetime oral exposure to tert-butanol is 5 × 10^−4^ per mg/kg-day, based on the thyroid follicular cell adenoma or carcinoma response in male or female B6C3F1 mice. This slope factor should not be used with exposures exceeding 1,400 mg/kg-day, the highest POD from the two data sets, because above this level the cancer risk might not increase linearly with exposure. The slope of the linear extrapolation from the central estimate BMD_10HED_ derived from the female mouse data set is 0.1 ÷ [0.14 × (2,002 mg/kg-day)] = 4 × 10^−4^ per mg/kg-day.

Table 2-8 Summary of the oral slope factor derivation

Tumor | Species/sex | Selected model | BMR | BMD (mg/kg-d) | POD = BMDL (mg/kg-d) | BMDL_HED_^a^ (mg/kg-d) | Slope factor^b^ (mg/kg-d)^−1^
Thyroid follicular cell adenoma | B6C3F1 mouse/female | 3° Multistage | 10% | 2,002 | 1,437 | 201 | 5 × 10^−4^
Thyroid follicular cell adenoma or carcinoma | B6C3F1 mouse/male | All dose groups: 1° Multistage | 5%^c^ | 1,788 | 787 | 110 | 5 × 10^−4^
Thyroid follicular cell adenoma or carcinoma | B6C3F1 mouse/male | High dose omitted: 2° Multistage | 5%^c^ | 1,028 | 644 | 90 | 6 × 10^−4^

a HED PODs were calculated using BW^3/4^ scaling (U.S. EPA, 2011).

b Human equivalent slope factor = 0.1/BMDL_10HED_; see Appendix C of the Supplemental Information for details of modeling results. These values are notably uncertain because it is based on a determination of suggestive evidence of carcinogenic potential; however, the slope factors may be useful for some decision purposes such as providing a sense of the magnitude of potential risks or ranking potential hazards (U.S. EPA, 2005a). The uncertainties in the data leading to this suggestive weight of evidence determination for carcinogenicity are detailed in Section 2.3.4. below.

c Because the observed responses were <10%, a BMR of 5% was used to represent the observed response range for low-dose extrapolation; human equivalent slope factor = 0.05/BMDL_5HED_.

### 2.3.4 Uncertainties in the Derivation of the Oral Slope Factor

There is uncertainty when extrapolating data from animals to estimate potential cancer risks to human populations from exposure to tert-butanol.

Table 2-9 summarizes several uncertainties that could affect the oral slope factor. There are no other chronic studies to replicate these findings or that examined other animal models, no data in humans to confirm a cancer response in general or the specific tumors observed in the NTP (1995) bioassay, and no other data (e.g., MOA) to support alternative approaches for deriving the oral slope factor.

Table 2-9 Summary of uncertainties in the derivation of the oral slope factor for tert-butanol

Consideration and impact on cancer risk value | Decision | Justification
Selection of tumor type and relevance to humans:; Mouse thyroid tumors are the basis for estimating human cancer risk, because the fraction of rat kidney tumors not attributed to the male rat-specific alpha 2μ-globulin process could not be determined. Alternatively, quantifying rat kidney tumors could ↑ slope factor to 1 × 10^−2^ mg/kg-d (see Appendix C, Supplemental Information) | Thyroid tumors in female and male mice were selected, U.S. EPA (1998a), U.S. EPA (1991a) | MOA data suggested that mouse thyroid tumors were relevant to humans. Quantitation of thyroid tumors in male mice, which was affected only slightly by high mortality in the high-dose group, supports the estimate based on female mice.
Selection of data set:; No other studies are available | NTP (1995), oral (drinking water) study, was selected to derive cancer risks for humans | NTP (1995), the only chronic bioassay available, was a well-conducted study. Additional bioassays might support the findings, help determine what fraction of kidney tumors are not attributable to the alpha 2μ-globulin process, or provide results for different (possibly lower) doses, which would affect (possibly increase) the oral slope factor.
Selection of dose metric:; Alternatives could ↓ or ↑ slope factor | Used administered dose | For mice, PBPK-estimated internal doses could affect the OSF value for thyroid tumors if the carcinogenic moiety is not proportional to administered dose, but no PBPK model was available, and no information is available to suggest if any metabolites elicit carcinogenic effects.
Interspecies extrapolation of dosimetry and risk:; Alternatives could ↓ or ↑ slope factor (e.g., 3.5-fold ↓ [scaling by body weight] or 2-fold ↑ [scaling by BW^2/3^]) | Default approach of body weight^3/4^ was used | No data to suggest an alternative approach for tert-butanol. Because the dose metric was not an area under the curve, BW^3/4^ scaling was used to calculate equivalent cumulative exposures for estimating equivalent human risks. Although the true human correspondence is unknown, this overall approach is expected to neither over- or underestimate human equivalent risks.
Dose-response modeling:; Alternatives could ↓ or ↑ slope factor | Used multistage dose-response model to derive a BMD and BMDL | No biologically based models for tert-butanol were available. The multistage model has biological support and is the model most consistently used in EPA cancer assessments.
Low-dose extrapolation:; ↓ cancer risk estimate would be expected by applying nonlinear low-dose extrapolation | Linear extrapolation of risk in low-dose region used U.S. EPA (1998a) | Linear low-dose extrapolation for agents without a known MOA is supported (U.S. EPA, 2005b) and recommended for rodent thyroid tumors arising from an unknown MOA (U.S. EPA, 1998a).
Statistical uncertainty at POD:; ↓ oral slope factor 1.4-fold if BMD used as the POD rather than BMDL | BMDL (preferred approach for calculating slope factor) | Limited size of bioassay results in sampling variability; lower bound is 95% confidence interval on administered exposure at 10% extra risk of thyroid tumors.
Sensitive subpopulations:; ↑ oral slope factor to unknown extent | No sensitive populations have been identified | No chemical-specific data are available to determine the range of human toxicodynamic variability or sensitivity, including the susceptibility of children. Because determination of a mutagenic MOA is not known, an age-specific adjustment factor is not applied.

### 2.3.5 Previous Integrated Risk Information System (IRIS) Assessment

No previous cancer assessment for tert-butanol is available in IRIS.

## 2.4 INHALATION UNIT RISK FOR CANCER

The carcinogenicity assessment provides information on the carcinogenic hazard potential of the substance in question, and quantitative estimates of risk from oral and inhalation exposure can be derived. Quantitative risk estimates can be derived from the application of a low-dose extrapolation procedure. If derived, the inhalation unit risk is a plausible upper bound on the estimate of risk per μg/m^3^ air breathed.

No chronic inhalation exposure studies to tert-butanol are available. Lifetime oral exposure has been associated with increased renal tubule adenomas and carcinoma in male F344 rats, increased thyroid follicular cell adenomas in female B6C3F1 mice, and increased thyroid follicular cell adenomas and carcinomas in male B6C3F1 mice. Although an oral slope factor was derived for tert-butanol based on increased thyroid tumors in mice; no mouse PBPK model exists for tert-butanol; therefore, RTR extrapolation (oral to inhalation) cannot be performed for thyroid tumors in mice at this time. The NTP (1995) drinking water study in rats and mice was the only chronic bioassay available for dose-response analysis. Still, the rat PBPK model and kidney tumors from the NTP (1995) drinking water study were not used for RTR extrapolation or the derivation of an OSF because enough information to determine the relative contribution of alpha 2u-globulin nephropathy and other processes to the overall renal tumor response (U.S. EPA, 1991a) is not available. As stated in (U.S. EPA, 1991a) “if some tumors are attributable to the alpha 2u-globulin process and some are attributable to other processes, such tumors remain relevant for purposes of hazard identification, but a dose response estimate based on such tumors in male rats should not be performed unless enough information is available to determine the relative contribution of each process to the overall tumor response.”

### 2.4.1 Previous Integrated Risk Information System (IRIS) Assessment

An inhalation cancer assessment for tert-butanol was not previously available on IRIS.

## 2.5 APPLICATION OF AGE-DEPENDENT ADJUSTMENT FACTORS

As discussed in the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005c), either default or chemical-specific age-dependent adjustment factors (ADAFs) are recommended to account for early-life exposure to carcinogens that act through a mutagenic MOA. Because chemical-specific lifestage susceptibility data for cancer are not available, and because the MOA for tert-butanol carcinogenicity is not known (see Section 1.3.2), application of ADAFs is not recommended.

11 This value is notably uncertain because it is based on a determination of suggestive evidence of carcinogenic potential: however, the value may be useful for some decision purposes such as providing a sense of the magnitude of potential risks or ranking potential hazards (U.S. EPA, 2005a). The uncertainties in the data leading to this suggestive weight of evidence determination for carcinogenicity are detailed in Section 2.3.4. below.