# 1 HAZARD IDENTIFICATION

## 1.1 OVERVIEW OF CHEMICAL PROPERTIES AND TOXICOKINETICS

### 1.1.1 Chemical Properties

tert-Butanol is a white crystalline solid or colorless, highly flammable liquid (above 25.7°C) with a camphor-like odor (NIOSH, 2005; IPCS, 1987). tert-Butanol contains a hydroxyl chemical functional group; is miscible with alcohol, ether, and other organic solvents; and is soluble in water (IPCS, 1987). Chemical and physical properties of tert-butanol are presented in Table 1-1.

### 1.1.2 Toxicokinetics

tert-Butanol is rapidly absorbed following exposure through oral and inhalation routes (see Appendix B, Section B.1.1). Studies in experimental animals indicate that 99% of the compound is absorbed after oral administration. Comparable blood levels of tert-butanol and its metabolites also have been observed after acute oral or inhalation exposures in rats (ARCO, 1983). In another study (Faulkner et al., 1989), blood concentrations indicated that absorption was complete at 1.5 hours following oral gavage doses of tert-butanol in female mice.

tert-Butanol is distributed throughout the body following oral, inhalation, and intravenous exposures (Poet et al., 1997; Faulkner et al., 1989; ARCO, 1983). Following exposure to tert-butanol in rats, tert-butanol was found in kidney, liver, and blood, with male rats retaining more tert-butanol than female rats (Williams and Borghoff, 2001).

A general metabolic scheme for tert-butanol, illustrating the biotransformation in rats and humans, is shown in Figure 1-1 (see Appendix B, Section B.1.3).

Human data on the excretion of tert-butanol comes from studies of methyl tert-butyl ether (MTBE) and ethyl tertiary butyl ether [ETBE; Nihlén et al. (1998a, 1998b)]. The half-life of tert-butanol in urine following MTBE exposure was 8.1 ± 2.0 hours (average of the 90.1- and 757-mg/m^3^ MTBE doses); the half-life of tert-butanol in urine following ETBE exposure was 7.9 ± 2.7 hours (average of 104- and 210-mg/m^3^ ETBE doses). These studies reported urinary levels of tert-butanol (not including downstream metabolites) to be less than 1% of administered MTBE or ETBE concentrations (Nihlén et al., 1998a, b). Amberg et al. (2000) observed a similar half-life of 9.8 ± 1.4 hours after human exposure to ETBE of 170 mg/m^3^. The half-life for tert-butanol in rat urine was 4.6 ± 1.4 hours at ETBE levels of 170 mg/m^3^.

A more detailed summary of tert-butanol toxicokinetics is provided in Appendix B, Section B.1.

Table 1-1 Chemical identity and physicochemical properties of tert-Butanol as curated by EPA’s CompTox Chemicals Dashboard

Characteristic or property | Value
Chemical structure | Chemical structure
CASRN | 75–65–0
Synonyms | 2-Propanol, 2-methyl-, 1,1-dimethylethanol, 2-methylpropan-2-ol, 2-methylpropan-2-ol (other name: tert-butylalcohol), 2-methylpropane-2-ol, 2-metilpropan-2-ol, t-butanol, trimethyl carbinol, trimethylcarbinol, trimethylmethanol, arconol, t-butyl hydroxide, tert-butanol, (see https://comptox.epa.gov/dashboard for additional synonyms)
Molecular formula | C_4_H_10_O
Molecular weight (g/mol) | 74.123
| Average experimental value^a^ | Average predicted value^a^
Flash point (°C) | — | 17.5
Boiling point (°C) | 82.8 | 79.7
Melting point (°C) | 25.2 | −30.4
Log K_ow_ | 3.50 | 3.78
Water solubility (mol/L) | 13.5 | 3.61
Density (g/cm^3^) | — | 0.833
Henry’s law constant (atm-m^3^/mole) | 9.05 × 10^−6^ | 9.01 × 10^−6^
Vapor pressure (mm Hg at 20°C) | 40.7 | 52.7

atm = atmosphere; CASRN = Chemical Abstracts Service registry number.

a Median values and ranges for physicochemical properties are also provided on the CompTox Chemicals Dashboard at https://comptox.epa.gov/dashboard/.

Figure 1-1 Biotransformation of tert-butanol in rats and humans

Source: NSF International (2003), ATSDR (1996), Bernauer et al. (1998), Amberg et al. (1999), and Cederbaum and Cohen (1980).

### 1.1.3 Description of Toxicokinetic Models

While no models of tert-butanol have been created independently of other chemicals from which it arises as a metabolite (e.g., MTBE, ETBE), tert-butanol submodels have been adapted specifically to estimate internal doses for administration of tert-butanol. In particular, some of these tert-butanol submodels were parameterized using pharmacokinetic studies with tert-butanol exposures. Three physiologically based pharmacokinetic (PBPK) models [Leavens and Borghoff (2009); Salazar et al. (2015), and Borghoff et al. (2016)] have been developed that can be used to simulate direct administration of tert-butanol, as well as its parent compound, in rats. Other models have incorporated tert-butanol as a submodel following MTBE administration but were not considered further because they do not include terms for direct exposure to tert-butanol (e.g., Rao and Ginsberg (1997)). In Leavens and Borghoff (2009), tert-butanol is incorporated as a metabolite of MTBE: in Salazar et al. (2015) and Borghoff et al. (2016), it is incorporated as a metabolite of ETBE. With all three models, inhalation and oral exposure to tert-butanol can be simulated in rats (i.e., with exposure to the parent MTBE or ETBE set to zero). A more detailed summary and evaluation of the toxicokinetic models is provided in Appendix B of the Supplemental Information (see Sections B.1.5 and B.1.7).

### 1.1.4 Chemicals Extensively Metabolized to tert-Butanol

tert-Butanol is a metabolite of other compounds, including ETBE, MTBE, and tert-butyl acetate. Some of the toxicological effects observed for these compounds are attributed to tert-butanol. Animal studies demonstrate that chronic exposure to ETBE is associated with noncancer kidney effects, including increased kidney weights in male and female rats accompanied by increased chronic progressive nephropathy (CPN), urothelial hyperplasia (in males), and increased blood concentrations of total cholesterol, blood urea nitrogen, and creatinine (Saito et al., 2013; Suzuki et al., 2012). In these studies, increased liver weight and centrilobular hypertrophy also were observed in male and female rats exposed to ETBE. Liver adenomas and carcinomas were increased in male rats following 2-year inhalation exposure (Saito et al., 2013).

In 1996, the U.S. Agency for Toxic Substances and Disease Registry’s (ATSDR) Toxicological Profile for MTBE (ATSDR, 1996) identified cancer effect levels of MTBE based on carcinogenicity data in animals. ATSDR reported that inhalation exposure was associated with kidney cancer in rats and liver cancer in mice. ATSDR concluded that oral exposure to MTBE might cause liver and kidney damage and nervous system effects in rats and mice. The chronic inhalation minimal risk level was derived based on incidence and severity of chronic progressive nephropathy in female rats (ATSDR, 1996). In 1997, EPA’s Office of Water concluded that MTBE is carcinogenic to animals and poses a potential carcinogenic potential to humans based on an increased incidence of Leydig cell adenomas of the testes, kidney tumors, lymphomas, and leukemia in exposed rats (U.S. EPA, 1997). In 1998, the International Agency for Research on Cancer (IARC) found “limited evidence” of MTBE carcinogenicity in animals and placed MTBE in Group 3 [i.e., not classifiable as to carcinogenicity in humans; IARC (1999)]. IARC reported that oral exposure in rats resulted in testicular tumors in males and lymphomas and leukemias (combined) in females; inhalation exposure in male rats resulted in renal tubule adenomas; and inhalation exposure in female mice resulted in hepatocellular adenomas (IARC, 1999).

No assessments by national or international agencies or chronic studies for tert-butyl acetate are available.

## 1.2 PRESENTATION AND SYNTHESIS OF EVIDENCE BY ORGAN/SYSTEM

### 1.2.1 Kidney Effects

#### Synthesis of Effects in Kidney

This section reviews the studies that investigated whether subchronic or chronic exposure to tert-butanol can affect kidneys in humans or animals. The evidence base examining kidney effects following tert-butanol exposure contains eight studies (from five references) performed in rats or mice (Huntingdon Life Sciences, 2004; Acharya et al., 1997; NTP, 1997; Acharya et al., 1995; NTP, 1995) and a reevaluation of the rat data from NTP (1995), published by Hard et al. (2011) and Hard et al. (2019); no human data are available. Studies using short-term and acute exposures that examined kidney effects are not included in the evidence tables; they are discussed in the text, however, if they provide data to inform mode of action (MOA) or hazard identification. tert-Butanol exposure resulted in kidney effects after both oral (drinking water) and inhalation exposure in both sexes of rats (see Table 1-2, Table 1-3, Figure 1-2, and Figure 1-3); studies are arranged in the evidence tables first by effect, then by route, and then duration.

The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment. Interpretation of nonneoplastic kidney endpoints in rats, however, is complicated by the common occurrence of age-related, spontaneous lesions characteristic of chronic progressive nephropathy [NTP (2015); Hard et al. (2013); Melnick et al. (2012); U.S. EPA (1991a); http://ntp.niehs.nih.gov/nnl/urinary/kidney/necp/index.htm]. CPN is more severe in male rats than in females and is particularly common in the Sprague-Dawley and Fischer 344 strains. Dietary and hormonal factors play a role in modifying CPN, although the etiology is largely unknown (see further discussion below).

Kidney weight. Kidney weight was observed to increase in male and female F344 rats following exposures of 13 weeks [oral and inhalation; NTP (1997)] and 15 months [oral; NTP (1995)]. Huntingdon Life Sciences (2004) also reported increased kidney weight in Sprague-Dawley rats administered tert-butanol orally for approximately 10 weeks (tabular data on relative and absolute kidney weights are presented in the Supplemental Information to this Toxicological Review). A dose-related increase in absolute kidney weight was also observed in both male and female rats (Spearman’s rank coefficient [rho] > 0.72) following either oral or inhalation exposures (see Figure 1-4, Figure 1-5, and Figure 1-6), and in female mice following inhalation exposure (rho = 0.9).

Measures of relative, as opposed to absolute, organ weight are sometimes preferred because they account for changes in body weight that might influence changes in organ weight (Bailey et al., 2004), although the potential impact of both should be evaluated. However, for tert-butanol, body weight in exposed animals noticeably decreased at the high doses relative to controls in the oral 13-week and 2-year studies (NTP, 1995). Thus, use of relative organ-weight change would not be a reliable measure of kidney-weight change for this assessment. Although relative and absolute kidney-weight data are both presented in exposure-response arrays (and in evidence tables in Appendix B of the Supplemental Information), the absolute measures were considered more informative for determining tert-butanol hazard potential. Support for this judgement can be found in a 2014 analysis indicating that increased absolute, but not relative, subchronic kidney weights are significantly correlated with chemically induced histopathological findings in the kidney in chronic and subchronic studies (Craig et al., 2015).

Kidney histopathology. Treatment-related histopathological changes were observed in the kidneys of male and female F344 rats following 13-week and 2-year oral exposures (NTP, 1995) and in male F344 rats following a 13-week inhalation exposure (NTP, 1997). Similarly, male Wistar rats exposed for approximately 10 weeks exhibited an increase in histopathological kidney lesions (Acharya et al., 1997; Acharya et al., 1995). For B6C3F1 mice, however, the study authors did not report histopathological changes for mice exposed for 13 weeks and 2 years to tert-butanol via the oral route (NTP, 1995) and 13 weeks via the inhalation route (NTP, 1997). More specific details on the effects observed in rats, reported by NTP (1997, 1995) and Acharya et al. (1997); (1995) are described below.

Nephropathy and severity of nephropathy were reported in male and female rats in the 13-week oral studies (NTP, 1995). The nephropathy was characterized as “…a spontaneous background lesion…typically consist[ing] of scattered renal tubules lined by basophilic regenerating tubule epithelium” (NTP, 1995). NTP (1995) noted that the increase in severity of nephropathy was related to tert-butanol and “characterized by an increase in the number and size of foci of regeneration.” Compared with controls, the severity of nephropathy increased in the 13-week male rats, which exhibited nephropathy in 94% of all exposed animals and 70% of controls. Conversely, lesion severity was unchanged in the females, although nephropathy incidence significantly increased with tert-butanol exposure. In the 13-week inhalation study (NTP, 1997), nephropathy was present in all but two male rats, including controls. NTP (1997) characterized the reported chronic nephropathy in control male rats as “1 to 3 scattered foci of regenerative tubules per kidney section. Regenerative foci were characterized by tubules with cytoplasmic basophilia, increased nuclear/cytoplasmic ratio, and occasionally thickened basement membranes and intraluminal protein casts.” In exposed groups, the severity generally increased from minimal to mild with increasing dose as “evidenced by an increased number of foci.” No treatment-related kidney histopathology was reported in the female rats exposed through inhalation (NTP, 1997).

In the 2-year oral study by NTP (1995), nephropathy was reported at 15 months and 2 years. The NTP (1995) characterization of nephropathy following chronic exposure included multiple lesions: “thickened tubule and glomerular basement membranes, basophilic foci of regenerating tubule epithelium, intratubule protein casts, focal mononuclear inflammatory cell aggregates within areas of interstitial fibrosis and scarring, and glomerular sclerosis.” At 15 months, male and female rats (30/30 treated; 10/10 controls) had nephropathy, and the severity scores ranged from minimal to mild. At 2 years, male and female rats (149/150 treated; 49/50 controls) also had nephropathy, and although the severity was moderate in the control males and minimal to mild in the control females, severity increased with tert-butanol exposure in both sexes (NTP, 1995).

The lesions collectively described by NTP (1997, 1995) as nephropathy and noted as common spontaneous lesions in rats are consistent with CPN. CPN is not a specific diagnosis per se but rather an aggregate term describing a spectrum of effects. In addition, no known counterpart to CPN has been identified in the aging human kidney. However, several individual lesions noted in CPN (e.g., tubule atrophy, tubule dilation, thickening of tubular basement membranes, glomerulosclerosis) also occur in the human kidney (Lusco et al., 2016; Zoja et al., 2015; Frazier et al., 2012; Satirapoj et al., 2012). Therefore, exacerbation of one or more of these lesions following tert-butanol exposure may reflect some type of cell injury or inflammatory process that is relevant to the human kidney.

Several factors, including genetic predisposition, increased glomerular permeability, elevated protein loads, and hemodynamic changes in the kidney, may play a role in the progression of CPN; however, no etiological factors have been clearly identified (NIEHS, 2019). The effects characterized as CPN are related to age (increased severity and incidence) and strain (higher in Sprague-Dawley rats compared with other strains); they are not considered histopathological manifestations of chemically induced toxicity (NIEHS, 2019) [see U.S. EPA (1991a), p. 35 for further details and a list of the typical, observable histopathological features of CPN]. These lesions, however, are frequently exacerbated by tert-butanol treatment (NTP, 1997), as evidenced by the dose-related increases in severity of the nephropathy compared with female and male rat controls. The chemical-related changes in increased severity of nephropathy are included in the consideration of hazard potential.

NTP (1995) observed other kidney lesions, described as being associated with nephropathy but diagnosed separately. Renal mineralization is defined by NTP (1995) as “focal mineral deposits primarily at the corticomedullary junction.” Renal (corticomedullary) mineralization was observed in essentially all female rats at all reported treatment durations. NTP (1995) described focal, medullary mineralization as being associated with CPN but noted that focal mineralization is “usually more prominent in untreated females than in untreated males,” which is consistent with the widespread appearance of this lesion in females. Corticomedullary mineralization (also referred to as nephrocalcinosis) in the rat is a common (especially in females) background/incidental finding that is not generally considered to be clinically important to rats or relevant to human health (Frazier et al., 2012). Thus, corticomedullary mineralization was not included in the consideration of hazard potential.

A dose-related, increased incidence of renal mineralization was reported in male rats at the end of the 13-week, 15-month, and 2-year oral evaluations (NTP, 1995). This mineralization is distinct from linear mineralization, which is considered a lesion characteristic of alpha 2u-globulin nephropathy (for further discussion of this particular lesion, see Mode of Action Analysis—Kidney Effects). Linear mineralization is characterized as distinct linear deposits along radiating medullary collecting ducts. An increased incidence of linear mineralization was limited to exposed males in the 2-year oral study (NTP, 1995). Linear mineralization was not included in the consideration of hazard potential.

Two other histological kidney lesions observed in male and female rats are suppurative inflammation and transitional epithelial hyperplasia (also known as urothelial hyperplasia). These lesions were observed in the 2-year oral NTP (1995) study. NTP (1995) and Frazier et al. (2012) described these lesions as related to the nephropathy (characterized above as common and spontaneous and considered CPN). However, suppurative inflammation and urothelial hyperplasia are typically not related to CPN or are noted as secondary changes to CPN and not a direct result of CPN (NIEHS, 2019). Incidence of suppurative inflammation in female rats was low in the control group and increased with dose, with incidences ≥24% in the two highest dose groups, compared with controls. In comparison, 20% of the control males exhibited suppurative inflammation, and the changes in incidence were not dose related (incidences ranging from 18 to 36%). To determine whether the severity of these lesions was positively associated with the severity of nephropathy, contingency tables comparing the occurrence of suppurative inflammation with nephropathy in individual rats were arranged by severity and analyzed with Spearman’s rank correlation tests to determine strength of associations for each comparison (see Table 1-4 and Table 1-5). Suppurative inflammation and nephropathy were moderately correlated in females (rho = 0.47) and weakly correlated in males (rho = 0.17). The data indicate that CPN correlates with the induction of suppurative inflammation; however, the inflammation in female rats is also treatment related. Given that CPN is also dose-dependently increased in male and female rats (Salazar et al., 2015), disentangling the relative contribution of CPN and tert-butanol in the exacerbation of suppurative inflammation is problematic.

Transitional epithelial hyperplasia (also known as urothelial hyperplasia) was observed in both male and female rats exposed orally (NTP, 1995). In the control males, 50% of the animals exhibited transitional epithelial hyperplasia and the incidence and severity increased with dose. Only the mid- and high-dose females, however, exhibited dose-related increases in incidence and severity of transitional epithelial hyperplasia. This type of lesion was not reported in the control or low-dose females. NTP (1995) described transitional epithelial hyperplasia as increased layers of the transitional epithelial lining of the renal pelvis; the study authors noted no progression of this hyperplastic lesion to neoplasia. To determine whether the severity of the hyperplasia was positively associated with the severity of nephropathy, contingency tables comparing the occurrence of transitional epithelial hyperplasia with nephropathy in individual rats were arranged by severity and analyzed with Spearman’s rank correlation tests to determine strength of associations for each comparison (see Table 1-6 and Table 1-7). Transitional epithelial hyperplasia and nephropathy were strongly correlated (rho = 0.66) in males and moderately correlated (rho = 0.44) in females. The transitional epithelial hyperplasia observed in male and female rats is consistent with advanced CPN (Frazier et al., 2012). Similar to suppurative inflammation, transitional epithelial hyperplasia is both increased by dose and correlated with nephropathy, which is also dose related. Thus, disentangling the contributions of dose and nephropathy in the development of transitional epithelial hyperplasia is not possible. Transitional epithelial hyperplasia should not be confused with another lesion noted in the 2-year evaluation, renal tubule hyperplasia, which was considered preneoplastic (for further details regarding this type of hyperplasia, see the discussion under Kidney tumors, below).

Additional histopathological changes, including increased tubular degeneration, degeneration of the basement membrane of the Bowman’s capsule, diffused glomeruli, and glomerular vacuolation were noted in a 10-week study in male Wistar rats (Acharya et al., 1997; Acharya et al., 1995). A decrease in glutathione in the kidney accompanied these changes, which the study authors noted as potentially indicative of oxidative damage. Acharya et al. (1997) and Acharya et al. (1995) used one dose and a control group and did not report incidences. The increased tubule degeneration and glomerular vacuolation could be characterized as tubular atrophy and glomerular hyalinization, respectively, consistent with CPN; however, without quantitative information, examining the differences between the control and treated animals to determine whether CPN plays a role in development of these effects is not possible. Although based on the noted appearance of the effects in the treated animals compared with controls, the effects likely are treatment related.

Serum or urinary biomarkers informative of kidney toxicity were not measured in the studies discussed above. Some changes occurred in urinalysis parameters (e.g., decreased urine volume and increased specific gravity), accompanied by reduced water consumption, and thus, might not be related to an effect of kidney function (NTP, 1995).

Kidney tumors. The kidney is also a target organ for cancer effects following long-term exposure to tert-butanol (see Table 1-3, Figure 1-2). Male F344 rats had an increased incidence of combined renal tubule adenomas or carcinomas in the 2-year oral bioassay (Hard et al., 2011; NTP, 1995). The increase in tumors from control was similar in the low- and high-dose groups and highest in the mid-dose group. Overall, tumor increases were statistically significant in trend testing, which accounted for mortality (p ≤ 0.018). At the highest exposure group in male rats, the mean body weight decreased by 24%, raising some question as to whether the kidney tumors observed in the mid-dose group in male rats were solely the result of excessive toxicity rather than the carcinogenicity of tert-butanol. EPA Cancer Guidelines (U.S. EPA, 2005a) discusses the determination of an “excessively high dose” as compared to an “adequate high dose” and describes the process as one of expert judgment, which requires that “adequate data demonstrate that the effects are solely the result of excessive toxicity rather than the carcinogenicity of the tested agent.” In the 2-year oral bioassay (NTP, 1995), the study authors did not report exposure-related overt toxicity in male rats or any changes in toxicokinetics at the middle or high doses. Furthermore, the tumor incidence at the high dose in male rats, which had a final body-weight reduction of 24%, was not significantly different from controls. Mortality increased with increasing exposure (p = 0.001) over the 2-year exposure period; however, increased mortality does not correlate with the highest tumor incidence occurring at the middle dose.

Increases in incidence and severity of renal tubule hyperplasia also were observed in male rats. NTP (1995) stated that “[t]he pathogenesis of proliferative lesions of renal tubule epithelium is generally considered to follow a progression from hyperplasia to adenoma to carcinoma (Hard, 1986).” Similarly, EPA considered the renal tubule hyperplasia to be a preneoplastic effect associated with the renal tubule tumors. Renal tubule hyperplasia was found in one high-dose female (NTP, 1995); no increase in severity was observed and no tumors were reported in female rats. Therefore, this effect in females, which was not considered toxicologically significant, is not discussed further. Two renal tubular adenocarcinomas in male mice also were reported (NTP, 1995), one each in the low- and high-dose groups, but were not considered by National Toxicology Program (NTP) to be “biologically noteworthy changes”; thus, the tumors in mice are not discussed further.

A Pathology Working Group, sponsored by Lyondell Chemical Company, reevaluated the kidney changes in the NTP 2-year study to determine whether additional histopathological changes could be identified to inform the MOA for renal tubule tumor development (Hard et al., 2011). Working group members were blinded to treatment groups and used guidelines published by Hard and Wolf (1999) and refinements reported by Hard and Seely (2005), Hard and Seely (2006), and Hard (2008). The group’s report and analysis by Hard et al. (2011) confirmed the NTP findings of renal tubule hyperplasia and renal tubule tumors in male rats at 2 years. Not all findings were considered nephrotoxic responses; for example, the study authors considered transitional hyperplasia secondary to CPN. In particular, they reported similar overall tumor incidences in the exposed groups. Hard et al. (2011), however, reported fewer renal tubule adenomas and carcinomas in the control group than in the original NTP study. As a result, all treated groups had statistically significant increases in renal tubule adenomas and carcinomas (combined) compared with controls. Additionally, Hard et al. (2011) considered fewer tumors to be carcinomas than did the original NTP study. Results of both NTP (1995) and the reanalysis by Hard et al. (2011) are included in Table 1-3 and Figure 1-2.

Figure 1-2 Exposure response array for kidney effects following oral exposure to tert-butanol

Sources: (A) Acharya et al. (1997); (1995); (B) Hard et al. (2011)^a^

a Reanalysis of NTP (1995).

; (C) Huntingdon Life Sciences (2004); (D) NTP (1995).

Figure 1-3 Exposure-response array of kidney effects following inhalation exposure to tert-butanol (13-week studies, no chronic studies available)

Source: NTP (1997).

Figure 1-4 Comparison of absolute kidney-weight change in male and female rats across oral and inhalation exposure based on internal blood concentration

Spearman’s rank correlation coefficient (rho) was calculated to evaluate the direction of a monotonic association (e.g., positive value = positive association) and the strength of association

Sources: NTP (1997); NTP (1995).

Figure 1-5 Comparison of absolute kidney-weight change in male and female mice following oral exposure based on administered concentration

Spearman’s rank correlation coefficient (rho) was calculated to evaluate the direction of a monotonic association (e.g., positive value = positive association) and the strength of association

Source: NTP (1995).

Figure 1-6 Comparison of absolute kidney-weight change in male and female mice following inhalation exposure based on administered concentration

Spearman’s rank correlation coefficient (rho) was calculated to evaluate the direction of a monotonic association (e.g., positive value = positive association) and the strength of association

Source: NTP (1997).

Table 1-2 Changes in kidney histopathology in animals following exposure to tert-butanol

Reference and study design | Results
Acharya et al. (1997); Acharya et al. (1995); Wistar rat; 5–6 males/treatment; Drinking water (0 or 0.5%), 0 or 575 mg/kg-d 10 wk | ↑ tubular degeneration, degeneration of the basement membrane of the Bowman’s capsule, diffused glomeruli, and glomerular vacuolation (no incidences reported); ↓ kidney glutathione (^~^40%)^a^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | Incidence (severity):
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | Male | | | Female
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | Dose (mg/kg-d) | Mineralization^c^ | Nephrop-athy^d^ | Dose (mg/kg-d) | Mineralization^c^ | Nephrop-athy^d^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 0 | 0/10 | 7/10 (1.0) | 0 | 10/10 (1.7) | 2/10 (1.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 230 | 0/10 | 10/10 (1.6^a^) | 290 | 10/10 (2.0) | 3/10 (1.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 490 | 2/10 (1.5) | 10/10 (2.6^a^) | 590 | 10/10 (2.0) | 5/10 (1.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 840 | 8/10^a^ (1.4) | 10/10 (2.7^a^) | 850 | 10/10 (2.0) | 7/10^a^ (1.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 1,520 | 4/10^a^ (1.0) | 10/10 (2.6^a^) | 1,560 | 10/10 (2.0) | 8/10^a^ (1.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 230,490,840,1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850,1,560, or 3,620^b^ mg/kg-d; 13 wk | 3,610^b^ | 4/10^a^ (1.0) | 7/10 (1.1) | 3,620^b^ | 6/10 (1.2) | 7/10^a^ (1.0)
NTP (1995); B6C3F1 mouse; 10/sex/treatment; Drinking water (0, 2.5, 5,10, 20, or 40 mg/mL); M: 0, 350, 640,1,590, 3,940, or 8,210^b^ mg/kg-d; F: 0, 500, 820,1,660, 6,430, or 11,620^b^ mg/kg-d; 13 wk | Study authors indicated no treatment-related changes in kidney-related histopathology (histopathological data not provided for the 13-wk study)
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo interim); Drinking water (0,1.25, 2.5, 5, or 10 mg/mL); M: 0,90, 200, or 420^b^ mg/kg-d; F: 0,180, 330, or 650^b^ mg/kg-d; 2 yr | Incidence (severity):
| Male
| Dose (mg/kg-d) | Mineralization^c^ (interim) | Mineralization^c^ (terminal) | Linear mineralization^c^ (terminal)
| 0 | 1/10 (1.0) | 26/50 (1.0) | 0/50
| 90 | 2/10 (1.0) | 28/50 (1.1) | 5/50^a^ (1.0)
| 200 | 5/10 (1.8) | 35/50 (1.3) | 24/50^a^ (1.2)
| 420^b^ | 9/10^a^ (2.3) | 48/50^a^ (2.2) | 46/50^a^ (1.7)
| Dose (mg/kg-d) | Transitional epithelial hyperplasia | Nephropathy^d^ severity | Inflammation (suppurative) incidence
| 0 | 25/50 (1.7) | 3.0 | 10/50
| 90 | 32/50 (1.7) | 3.1 | 18/50
| 200 | 36/50^a^ (2.0) | 3.1 | 12/50
| 420^b^ | 40/50^a^ (2.1) | 3.3^a^ | 9/50
| Female
| Dose (mg/kg-d) | Mineralization^c^ (interim) | Mineralization^c^ (terminal) | Inflammation (suppurative) incidence
| 0 | 10/10 (2.8) | 49/50 (2.6) | 2/50
| 180 | 10/10 (2.9) | 50/50 (2.6) | 3/50
| 330 | 10/10 (2.9) | 50/50 (2.7) | 13/50^a^
| 650^b^ | 10/10 (2.8) | 50/50 (2.9) | 17/50^a^
| Dose (mg/kg-d) | Transitional epithelial hyperplasia | Nephropathy^d^ severity
| 0 | 0/50 | 1.6
| 180 | 0/50 | 1.9^a^
| 330 | 3/50 (1.0) | 2.3^a^
| 650^b^ | 17/50^a^ (1.4) | 2.9^a^
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5,10, or 20 mg/mL); M: 0, 540,1,040, or 2,070^b^ mg/kg-d; F: 0, 510,1,020, or 2,110 mg/kg-d; 2 yr | No treatment-related changes in kidney-related histopathology observed
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0,134, 272, 542, 1,080, or 2,101 ppm (0,406,824, 1,643, 3,273, or 6,368 mg/m^3^; dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | Male
| Concentration (mg/m^3^) | Incidence of chronic nephropathy^e^ | Average severity of chronic nephropathy
| 0 | 9/10 | 1.0
| 406 | 8/10 | 1.4
| 824 | 9/10 | 1.4
| 1,643 | 10/10 | 1.6
| 3,273 | 10/10 | 1.9
| 6,368 | 10/10 | 2.0
| Females: no treatment-related changes in kidney-related histopathology observed; Severity categories: 1 = minimal, 2 = mild. No results from statistical tests reported
NTP (1997); B6C3F1 mouse; 10/sex/treatment; Inhalation analytical concentration: 0,134, 272, 542, 1,080, or 2,101 ppm (0,406,824, 1,643, 3,273, or 6,368 mg/m^3^; dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No treatment-related changes in kidney-related histopathology observed

a Statistically significant p ≤ 0.05, as determined by the study authors.

b The high-dose group had an increase in mortality.

c Mineralization defined in NTP (1995) as focal mineral deposits, primarily at the corticomedullary junction. Linear mineralization was defined as foci of distinct linear deposits along radiating medullary collecting ducts; linear mineralization not observed in female rats.

d Nephropathy defined in NTP (1995) as lesions, including thickened tubule and glomerular basement membranes, basophilicfoci of regenerating tubule epithelium, intratubule protein casts, focal mononuclear inflammatory cell aggregates within areas of interstitial fibrosis and scarring, and glomerular sclerosis.

e Nephropathy characterized in NTP (1997) as scattered foci of regenerative tubules (with cytoplasmic basophilia, increased nuclear:cytoplasmic ratio, and occasionally thickened basement membranes and intraluminal protein casts).

Note: Conversions from drinking water concentrations to mg/kg-d were performed by the study authors. Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

Table 1-3 Changes in kidney tumors in animals following exposure to tert-butanol

Reference and study design | Results
NTP (1995) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=91022); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Male
| Dose (mg/kg-d) | Renal tubule hyperplasia (standard and extended evaluation combined) | Renal tubule adenoma (single) | | Renal tubule adenoma (multiple)
| 0 | 14/50 (2.3) | 7/50 | | 1/50
| 90 | 20/50 (2.3) | 7/50 | | 4/50
| 200 | 17/50 (2.2) | 10/50 | | 9/50^b^
| 420^a^ | 25/50^b^ (2.8) | 10/50 | | 3/50
| Dose (mg/kg-d) | Renal tubule carcinoma | Renal tubule adenoma (single or multiple) or carcinoma
| 0 | 0/50 | 8/50
| 90 | 2/50 | 13/50
| 200 | 1/50 | 19/50^b^
| 420^a^ | 1/50 | 13/50
| Female
| Dose (mg/kg-d) | Renal tubule hyperplasia | Renal tubule adenoma (single) | | Renal tubule adenoma (multiple)
| 0 | 0/50 | 0/50 | | 0/50
| 180 | 0/50 | 0/50 | | 0/50
| 330 | 0/50 | 0/50 | | 0/50
| 650^a^ | 1/50 (1.0) | 0/50 | | 0/50
| Dose (mg/kg-d) | Renal tubule carcinoma | Renal tubule adenoma (single or multiple) or carcinoma
| 0 | 0/50 | 0/50
| 180 | 0/50 | 0/50
| 330 | 0/50 | 0/50
| 650^a^ | 0/50 | 0/50
| Based on standard and extended evaluations (combined). Results do not include the animals sacrificed at 15 mo.
Hard et al. (2011); Reanalysis of the slides from male rats (all slides in control and high-dose groups of males and females, and slides from all other males with renal tumors) in the NTP (1995) study (see above) | Male
| Dose (mg/kg-d) | Renal tubule adenoma (single) | Renal tubule adenoma (multiple) | Renal tubule carcinoma | Renal tubule adenoma (single or multiple) or carcinoma
| 0 | 3/50 | 1/50 | 0/50 | 4/50
| 90 | 9/50 | 3/50 | 1/50 | 13/50^b^
| 200 | 9/50 | 9/50 | 0/50 | 18/50^b^
| 420 | 9/50 | 3/50 | 1/50 | 12/50^b^
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | No increases in kidney-related tumors. Two renal tubule adenocarcinomas, one in the low-dose and one in the high-dose groups, were observed in male mice. These tumors were not considered treatment related.

a The high-dose group had an increase in mortality.

b Statistically significant p ≤ 0.05, as determined by the study authors.

Note: Conversions from drinking water concentrations to mg/kg-d were performed by the study authors.

Table 1-4 Comparison of nephropathy and suppurative inflammation in individual male rats from the 2-year National Toxicology Program (NTP) tert-butanol bioassay

Suppurative inflammation | Nephropathy
Suppurative inflammation | None | Minimal | Mild | Moderate | Marked
None | 2 | 1 | 55 | 82 | 51
Minimal | 0 | 0 | 3 | 23 | 16
Mild | 0 | 0 | 1 | 4 | 2
Moderate | 0 | 0 | 0 | 0 | 0
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p = 0.0015, rho = 0.17.

Table 1-5 Comparison of nephropathy and suppurative inflammation in individual female rats from the 2-year National Toxicology Program (NTP) tert-butanol bioassay

Suppurative inflammation | Nephropathy
Suppurative inflammation | None | Minimal | Mild | Moderate | Marked
None | 7 | 67 | 90 | 37 | 4
Minimal | 0 | 1 | 5 | 14 | 13
Mild | 0 | 0 | 0 | 1 | 1
Moderate | 0 | 0 | 0 | 0 | 0
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p < 0.0001, rho = 0.47.

Table 1-6 Comparison of nephropathy and transitional epithelial hyperplasia in individual male rats from the 2-year National Toxicology Program (NTP) tert-butanol bioassay

Transitional epithelial hyperplasia | Nephropathy
Transitional epithelial hyperplasia | None | Minimal | Mild | Moderate | Marked
None | 2 | 1 | 51 | 52 | 1
Minimal | 0 | 0 | 4 | 26 | 9
Mild | 0 | 0 | 2 | 25 | 42
Moderate | 0 | 0 | 2 | 6 | 17
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p < 0.0001, rho = 0.66.

Table 1-7 Comparison of nephropathy and transitional epithelial hyperplasia in individual female rats from the 2-year National Toxicology Program (NTP) tert-butanol bioassay

Transitional epithelial hyperplasia | Nephropathy
Transitional epithelial hyperplasia | None | Minimal | Mild | Moderate | Marked
None | 7 | 68 | 95 | 43 | 7
Minimal | 0 | 0 | 0 | 8 | 6
Mild | 0 | 0 | 0 | 1 | 5
Moderate | 0 | 0 | 0 | 0 | 0
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p < 0.0001, rho = 0.437.

Table 1-8 Comparison of chronic progressive nephropathy and renal tubule hyperplasia with kidney adenomas and carcinomas in male rats from the 2-year National Toxicology Program (NTP) tert-butanol bioassay

CPN | Renal tumors absent | Renal tumors present | Renal tubule hyperplasia | Renal tumors absent | Renal tumors present
None | 2 | 0 | None | 133 | 29
Minimal | 1 | 0 | Minimal | 17 | 2
Mild | 57 | 2 | Mild | 17 | 13
Moderate | 93 | 16 | Moderate | 10 | 3
Marked | 34 | 35 | Marked | 10 | 6

Spearman’s rank correlation test (1-sided): CPN, p < 0.0001, rho = 0.430; renal tubule hyperplasia, p = 0.01, rho = 0.161.

#### Mode of Action Analysis—Kidney Effects

##### Alpha 2u-globulin-associated renal tubule nephropathy and carcinogenicity

One disease process to consider when interpreting kidney effects in rats is related to the accumulation of alpha 2u-globulin protein. Alpha 2u-globulin, a member of a large superfamily of low-molecular-weight proteins, was first characterized in male rat urine. Such proteins have been detected in various tissues and fluids of most mammals (including humans), but the particular isoform of alpha 2u-globulin commonly detected in male rat urine is considered specific to that sex and species. Exposure to chemicals that induce alpha 2u-globulin accumulation can initiate a sequence of histopathological events leading to kidney tumorigenesis. Because alpha 2u-globulin-associated renal tubule nephropathy and carcinogenicity occurring in male rats are presumed not relevant for assessing human health hazards (U.S. EPA, 1991a), evaluating the data to determine whether alpha 2u-globulin plays a role is important. The role of alpha 2u-globulin accumulation in the development of renal tubule nephropathy and carcinogenicity observed following tert-butanol exposure was evaluated using the U.S. EPA (1991a) Risk Assessment Forum Technical panel report, Alpha 2u-Globulin: Association with Chemically Induced Renal Toxicity and Neoplasia in the Male Rat as well as the IARC framework (Capen et al., 1999). These frameworks provide specific guidance for evaluating renal tubule tumors in male rats that are related to chemical exposure for the purpose of risk assessment, based on an examination of the potential involvement of alpha 2u-globulin accumulation.

Studies in the tert-butanol evidence base evaluated and reported effects on the kidney, providing some evidence to evaluate this MOA. Additionally, several studies were identified that specifically evaluated the role of alpha 2u-globulin in tert-butanol-induced renal tubule nephropathy and carcinogenicity (Borghoff et al., 2001; Williams and Borghoff, 2001; Takahashi et al., 1993). Because the evidence reported in these studies is specific to alpha 2u-globulin accumulation, it is presented in this section; it was not included in the animal evidence tables in the previous section.

The hypothesized sequence of alpha 2u-globulin renal tubule nephropathy, as described by U.S. EPA (1991a), is as follows. Chemicals that induce alpha 2u-globulin accumulation do so rapidly. Alpha 2u-globulin accumulating in hyaline droplets is deposited in the S2 (P2) segment of the proximal tubule within 24 hours of exposure. Hyaline droplets are a normal constitutive feature of the mature male rat kidney; they are particularly evident in the S2 (P2) segment of the proximal tubule and contain alpha 2u-globulin (U.S. EPA, 1991a). Abnormal increases in hyaline droplets have more than one etiology and can be associated with the accumulation of different proteins. As hyaline droplet deposition continues, single-cell necrosis occurs in the S2 (P2) segment, which leads to exfoliation of these cells into the tubule lumen within 5 days of chemical exposure. In response to the cell loss, cell proliferation occurs in the S2 (P2) segment after 3 weeks and continues for the duration of the exposure. After 2 or 3 weeks of exposure, the cell debris accumulates in the S3 (P3) segment of the proximal tubule to form granular casts. Continued chemical exposure for 3 to 12 months leads to the formation of calcium hydroxyapatite in the papillae, which results in linear mineralization. After 1 or more years of chemical exposure, these lesions can result in the induction of renal tubule adenomas and carcinomas (see Figure 1-7).

U.S. EPA (1991a) identified two questions that must be addressed to determine the extent to which alpha 2u-globulin-mediated processes induce renal tubule nephropathy and carcinogenicity. First, whether the alpha 2u-globulin process occurs in male rats and influences renal tubule tumor development must be determined. Second, whether the renal effects in male rats exposed to tert-butanol are due solely to the alpha 2u-globulin process must be determined.

U.S. EPA (1991a) stated the criteria for answering the first question in the affirmative are as follows:

1) Hyaline droplets are larger and more numerous in treated male rats;
2) The protein in the hyaline droplets in treated male rats is alpha 2u-globulin (i.e., immunohistochemical evidence); and
3) Several (but not necessarily all) additional steps in the pathological sequence appear in treated male rats as a function of time, dose, and progressively increasing severity consistent with the understanding of the underlying biology, as described above, and illustrated in Figure 1-7.

The available data relevant to this first question are summarized in Table 1-9, Figure 1-8, and Figure 1-9, and are evaluated below.

Figure 1-7 Temporal pathogenesis of alpha 2u-globulin-associated nephropathy in male rats

Alpha 2u-globulin synthesized in the livers of male rats is delivered to the kidney, where it can accumulate in hyaline droplets and be retained by epithelial cells lining the S2 (P2) segment of the proximal tubules. Renal pathogenesis following continued tert-butanol exposure and increasing droplet accumulation can progress stepwise from increasing epithelial cell damage, death, and dysfunction leading to the formation of granular casts in the corticomedullary junction, linear mineralization of the renal papillae, and carcinogenesis of the renal tubular epithelium

Source: Adapted from Swenberg and Lehman-McKeeman (1999) and U.S. EPA (1991a).

Table 1-9 Summary of data on the alpha 2u-globulin process in male rats exposed to tert-butanol

Duration | | Dose | Results | Comments | Reference
1) Hyaline droplets are increased in size and number
| 10 d (inhalation) | 0, 758, 1,364, 5,304 mg/m^3^ | + | stat sig at 5,304 mg/m^3^; stat sig trend | Borghoff et al. (2001)
| 13 wk (inhalation) | 0, 3,273, 6,368 mg/m^3^ | − | | NTP (1997) ^a^
| 13 wk (oral) | 0, 230, 490, 840, 1,520, 3,610 mg/kg-d | (+) | observed in all but highest dose group | NTP (1995)
2) The protein in the hyaline droplets is alpha 2u-globulin
| 10 d (inhalation) | 0, 758, 1,364, 5,304 mg/m^3^ | + | stat sig at 5,304 mg/m^3^; stat sig trend | Borghoff et al. (2001)
| 12 h (elapsed time following single oral dose) | 0, 500 mg/kg | + | | Williams and Borghoff (2001)
3) Several (but not necessarily all) additional steps in the pathological sequence are present in male rats, such as:
| a) Subsequent cytotoxicity and single-cell necrosis of tubule epithelium, with exfoliation of degenerate epithelial cells
| 10 wk (oral) | 0, 575 mg/kg-d | (+) | degeneration of renal tubules reported | Acharya et al. (1997)
| 13 wk (oral) | 0, 230, 490, 840, 1,520, 3,610 mg/kg-d | − | | NTP (1995)
| b) Sustained regenerative tubule cell proliferation (NOTE: The positive studies below reported cell proliferation but did not show necrosis or cytotoxicity; therefore, it cannot be assumed that the results indicate regenerative proliferation is occurring.)
| 10 wk (oral) | 0, 575 mg/kg-d | − | | Acharya et al. (1997)
| 10 d (inhalation) | 0, 758, 1,364, 5,304 mg/m^3^ | + | stat sig at all doses; stat sig trend | Borghoff et al. (2001)
| 13 wk (oral) | 0, 230, 490, 840, 1,520, 3,610 mg/kg-d | + | elevated at 840 mg/kg-d; stat sig at 1,520 mg/kg-d | NTP (1995)
| c) Development of intraluminal granular casts from sloughed cellular debris, with consequent tubule dilation
| 13 wk (oral) | 0, 230, 490, 840, 1,520, 3,610 mg/kg-d | −; (+)^b^ | | NTP (1995); Hard et al. (2011)^c^
| 2 yr (oral) | 0, 90, 200, 420 mg/kg-d | − | | NTP (1995); Hard et al. (2011)^d^
| d) Linear mineralization of tubules in the renal papilla
| 13 wk (oral) | 0, 230, 490, 840, 1,520, 3,610 mg/kg-d | − | | NTP (1995); Hard et al. (2011)^c^
| 2 yr (oral) | 0, 90, 200, 420 mg/kg-d | +; (+) | all doses stat sig | NTP (1995); Hard et al. (2011)^d^
| e) Foci of tubular hyperplasia
| 2 yr (oral) | 0, 90, 200, 420 mg/kg-d | + | stat sig trend at all doses; stat sig at 420 mg/kg-d | NTP (1995)

+ = Statistically significant change reported in one or more treated groups; (+) = Effect was reported in one or more treated groups, but statistics not reported; − = No statistically significant change reported in any of the treated groups; stat sig = statistically significant.

a NTP (1997) did not observe any effects consistent with alpha 2u-globulin nephropathy.

b Precursors to granular casts reported.

c Reanalysis of hematoxylin and eosin-stained kidney sections from all male control and 1,520-mg/kg-d groups and a representative sample of kidney sections stained with Mallory-Heidenhain stain, from the 13-wk study from NTP (1995).

d Reanalysis of slides for all males in the control and 420-mg/kg-d dose groups and all animals with renal tubule tumors from 2-yr (NTP, 1995). Protein casts reported, not granular casts.

Figure 1-8 Exposure-response array for effects potentially associated with alpha 2u-globulin renal tubule nephropathy and tumors in male rats after oral exposure to tert-butanol

*Hard et al. (2011) reported presence of “precursor granular casts.”

**NTP (1995) 13-wk study reported kidney mineralization but not linear mineralization.

Figure 1-9 Exposure-response array for effects potentially associated with alpha 2u-globulin renal tubule nephropathy and tumors in male rats after inhalation exposure to tert-butanol

###### Question One: is the alpha 2u-globulin process occurring in male rats exposed to tert-butanol?^9^

(1) The first criterion to consider is whether hyaline droplets are larger and more numerous in male rats exposed to tert-butanol. As noted above, the excessive accumulation of hyaline droplets can appear quickly, within 1 or 2 days, and persist throughout chronic exposures, although the severity begins to decline around 5 months (U.S. EPA, 1991a). A statistically significant positive trend in the accumulation of large protein droplets with crystalloid protein structures was observed in kidneys of male rats exposed to inhalation concentrations of 758, 1,364, and 5,304 mg/m^3^ tert-butanol for 6 hour/day for 10 days (Borghoff et al., 2001). These droplets were small and minimally present in control male rats and were not observed in female rats. Similarly, data from the 13-week NTP oral study (NTP, 1995; Takahashi et al., 1993; Lindamood et al., 1992) demonstrated an increase in the accumulation of hyaline droplets. The lowest dose group, 230 mg/kg-day, had minimal hyaline droplet formation compared with controls, although the next three dose groups (490, 840, and 1,520 mg/kg-day) had a higher accumulation of droplets with angular, crystalline structures that was similar in incidence and severity among these dose groups. No droplets were observed in female rats or in mice.

NTP (1997), however, found no difference between the control and treatment groups stained for hyaline droplet formation in male rats exposed to 0-, 3,273-, or 6,368-mg/m^3^ tert-butanol via inhalation for 13 weeks; in fact, this study reported no other lesions that could be specifically associated with alpha 2u-globulin nephropathy in male rats. These results from NTP (1997), which are inconsistent with the findings of both Borghoff et al. (2001) and NTP (1995), do not appear to be due to differences in dose. Comparison of the oral and inhalation studies on the basis of tert-butanol blood concentration (see Supplemental Information) showed that an exposure in the range of the NTP (1995) doses of 490-840 mg/kg-day for 13 weeks leads to the same average blood concentration as inhalation exposures to 3,273-6,368 mg/m^3^ for 6 hour/day, 5 day/week. The absence of similar histopathological findings in the 13-week inhalation NTP (1997) study compared with those reported in the two oral studies is not understood, but might be indicative of the strength of tert-butanol to induce, consistently, alpha 2u-globulin nephropathy. Also, it is possible that differences in the route of exposure may influence unknown mechanisms of action, The results from the two other studies (Borghoff et al., 2001; NTP, 1995) indicate that hyaline droplets increase in size and number in male rats following tert-butanol exposures. Despite the inconsistency, the findings from NTP (1995) and Borghoff et al. (2001), are considered as sufficient evidence to fulfill the first criterion that hyaline droplets are increased in size and number in male rats.

(2) The second criterion to consider is whether the protein in the hyaline droplets in male rats is alpha 2u-globulin. Accumulated hyaline droplets with an alpha 2u-globulin etiology can be confirmed by using immunohistochemistry to identify the alpha 2u-globulin protein. Two short-term studies measured alpha 2u-globulin immunoreactivity in the hyaline droplets of the renal proximal tubular epithelium (Borghoff et al., 2001; Williams and Borghoff, 2001). Following 10 days of inhalation exposure, Borghoff et al. (2001) did not observe an exposure-related increase in alpha 2u-globulin using immunohistochemical staining. However, when using an enzyme-linked immunosorbent assay (ELISA), considered by Borghoff et al. (2001) to be a more sensitive method of detecting alpha 2u-globulin, a statistically significant positive correlation of alpha 2u-globulin concentration with dose of tert-butanol was observed. The accumulation of alpha 2u-globulin protein was statistically significant by pairwise comparison only in the highest dose group. No positive staining for alpha 2u-globulin was observed in exposed female rats. In a follow-up study, Williams and Borghoff (2001) used a single gavage dose of 500 mg/kg [selected on the basis of results by NTP (1995) for induction of hyaline droplet accumulation] and reported a statistically significantly higher renal concentration of alpha 2u-globulin (by ELISA) in treated male rats than in controls 12 hours after exposure. Further, equilibrium dialysis methods determined that the binding of tert-butanol to alpha 2u-globulin was reversible. These data indicate the presence of alpha 2u-globulin in tert-butanol-treated male rats, although requiring a more sensitive method of detection for alpha 2u-globulin than is typically used could indicate that tert-butanol is not a strong inducer of alpha 2u-globulin accumulation. Therefore, the available data are sufficient to fulfill the second criterion for alpha 2u-globulin present in the hyaline droplets but suggest weak induction of alpha 2u-globulin by tert-butanol.

(3) The third criterion considered is whether several (but not necessarily all) additional events in the histopathological sequence associated with alpha 2u-globulin nephropathy appear in male rats in a manner consistent with the understanding of alpha 2u-globulin pathogenesis. Evidence of cytotoxicity and single-cell necrosis of the tubule epithelium subsequent to the excessive accumulation of hyaline droplets, with exfoliation of degenerate epithelial cells, should be observable after ~5 days of continuous exposure, peaking at ~19 days [reviewed in U.S. EPA (1991a)]. The formation and accumulation of granular casts from the exfoliated cellular debris would follow, causing tubule dilation at the junction of the S3 (P3) segment of the proximal tubule and the descending thin loop of Henle, and the commencement of compensatory cell proliferation within the S2 (P2) segment, both occurring after 3 weeks of continuous exposure. Following chronic exposures, this regenerative proliferation could result in focal tubular hyperplasia, and eventually progress to renal adenoma and carcinoma (see Figure 1-7).

Several of these steps were observed following tert-butanol exposure in male rats, most notably linear papillary mineralization and foci of tubular hyperplasia, consistent with the expected disease progression. Some lack of consistency and dose-related concordance, however, was evident across the remaining steps in the histopathological sequence. First, the accumulation of hyaline droplets and the concentrations of alpha 2u-globulin in the hyaline droplets at doses that induced significant tumor formation in male rats were not remarkable. Next, necrosis or cytotoxicity was absent, and only precursors to granular casts at stages well within the expected time frame of detectability were present. Finally, a 13-week inhalation study found no evidence of alpha 2u-globulin nephropathy (NTP, 1997), despite evaluating exposure concentrations predicted to result in similar blood tert-butanol levels as for the 13-week oral study (NTP, 1995), which reported increases in droplet accumulation and sustained regenerative tubule cell proliferation. A detailed evaluation and analysis of all the evidence relevant to this criterion follows.

###### Detailed evaluation of the available evidence supporting the third criterion

a. Single cell death and exfoliation into the renal tubules might logically be expected to accompany the occurrence of CPN, but this result was inconsistently observed. Single cell death or necrosis was not associated with tert-butanol exposure in male rat kidneys after 10 or 13 weeks (Acharya et al., 1997; NTP, 1995). Acharya et al. (1997) reported degeneration of renal tubules, one pathological consequence of single cell necrosis, in male rats exposed to tert-butanol in drinking water for 10 weeks. Because renal tubule epithelial cell death and epithelial degeneration should occur as early as 5 days post exposure and persist for up to 48 weeks (Swenberg and Lehman-McKeeman, 1999; Short et al., 1989), the lack of consistency in these observations could be due to both weak induction of alpha 2u-globulin and a lack of later examinations.
b. Sustained regenerative cell proliferation also might be logically expected to accompany the occurrence of CPN, but this result also was inconsistent. Acharya et al. (1997) did not observe tert-butanol-induced proliferation following 10 weeks of oral exposure but did observe renal tubule proliferation following another chemical exposure (trichloroacetic acid) in the same study. Therefore, the inference is that tert-butanol treatment did not induce regenerative tubule cell proliferation in male rats from this study. Borghoff et al. (2001), however, reported a dose-related increase in epithelial cell proliferation within the proximal tubule as measured by BrdU (bromodeoxyuridine) labeling indices in all male rats exposed to tert-butanol via inhalation for 10 days. The study did not report cytotoxicity and combined with the early time point makes it unlikely that the cell proliferation was compensatory. NTP (1995) also observed increased cell proliferation in the renal tubule epithelium following 13-week oral exposures in male rats [only male rats were studied in the retrospective analysis by Takahashi et al. (1993) reported in NTP (1995)]. Proliferation was elevated at 840-1,520 mg/kg-day, a range higher than the single 575-mg/kg-day dose that elicited epithelial degeneration (Acharya et al., 1997) and a result that could be consistent with a compensatory proliferative effect. NTP (1995), however, reported that no necrosis or exfoliation was observed. Altogether, proliferation and necrosis or degeneration were not observed within the same study despite several attempts to measure both effects. Thus, these data provide inadequate evidence to conclude that the proliferation was compensatory.
c. Granular cast formation was not observed, although one study noted precursors to cast formation. NTP (1995) did not observe the formation of granular casts or tubular dilation; however, Hard et al. (2011) reanalyzed the 13-week oral NTP data from male rats treated with 0 or 1,520 mg/kg-day and identified precursors to granular casts in 5/10 animals in the treated group. The significance of these granular cast precursors, described as sporadic basophilic tubules containing cellular debris, is unknown because 13 weeks of exposure is within the expected time frame of frank formation and accumulation of granular casts (≥3 weeks). Granular cast formation, however, might not be significantly elevated with weak inducers of alpha 2u-globulin (Short et al., 1986), which is consistent with the reported difficulty in measuring alpha 2u-globulin in hyaline droplets associated with tert-butanol exposure.
d. Linear mineralization of tubules within the renal papillae was consistently observed in male rats. This lesion typically appears at chronic time points, occurring after exposures of 3 months up to 2 years (U.S. EPA, 1991a). Consistent with this description, 2-year oral exposure to tert-butanol induced a dose-related increase in linear mineralization, but not following 13-week exposure [NTP (1995): see Table 1-2].
e. Renal tubule hyperplasia was observed in the only available 2-year study. Renal tubule hyperplasia is the preneoplastic lesion associated with alpha 2u-globulin nephropathy in chronic exposures that leads to renal tubule tumors (U.S. EPA, 1991a). A dose-related increase in renal tubule hyperplasia was observed in male rats following 2-year oral exposures (NTP, 1995). By comparison, renal tubule hyperplasia was observed in only one high-dose female.

The progression of histopathological lesions for alpha 2u-globulin nephropathy is predicated on the initial response of excessive hyaline droplet accumulation (containing alpha 2u-globulin) leading to cell necrosis and cytotoxicity, which in turn cause the accumulation of granular casts, linear mineralization, and tubular hyperplasia. Therefore, observations of temporal and dose-response concordance for these effects are informative for drawing conclusions on causation.

As mentioned above, most steps in the sequence of alpha 2u-globulin nephropathy are observed at the expected time points following exposure to tert-butanol. Accumulation of hyaline droplets was observed early, at 12 hours following a single bolus exposure (Williams and Borghoff, 2001) and at 10 days (Borghoff et al., 2001) or 13 weeks (NTP, 1995) following continuous exposure; alpha 2u-globulin was identified as the protein in these droplets (Borghoff et al., 2001; Williams and Borghoff, 2001). Lack of necrosis and exfoliation might be due to the weak induction of alpha 2u-globulin and a lack of later examinations. Granular cast formation was not reported in any of the available studies, which could also indicate weak alpha 2u-globulin induction. Regenerative cell proliferation, which was not observed, is discussed in more detail below. Observations of the subsequent linear mineralization of tubules and focal tubular hyperplasia fall within the expected time frame of the appearance of these lesions. Overall, no explicit inconsistencies are present in the temporal appearance of the histopathological lesions associated with alpha 2u-globulin nephropathy; however, the data set would be bolstered by measurements at additional time points to lend strength to the MOA evaluation.

Inconsistencies do occur in the dose-response among lesions associated with the alpha 2u-globulin nephropathy progression. Hyaline droplets were induced in the proximal tubule of all surviving male rats in the 13-week NTP oral study (NTP, 1995; Takahashi et al., 1993; Lindamood et al., 1992), although the incidence at the lowest dose was minimal, whereas the incidence at the three higher doses was more prominent. These results are discordant with the tumor results, given that all treated groups of male rats in the NTP 2-year oral bioassay had increased kidney tumor incidence, including the lowest dose of 90 mg/kg-day [according to the reanalysis by Hard et al. (2011)]. This lowest dose was less than the 230 mg/kg-day in the 13-week oral study that showed only minimal hyaline droplet formation. Furthermore, although the incidence of renal tubule hyperplasia had a dose-related increase (NTP, 1995), a corresponding dose-related increase in the severity of tubular hyperplasia did not result. Severity of tubule hyperplasia was increased only at the highest dose, which was not consistent with renal tumor incidence.

Although the histopathological sequence has data gaps, such as the lack of observable necrosis or cytotoxicity or granular casts at stages within the time frame of detectability, overall, a sufficient number of steps (e.g., linear papillary mineralization, foci of tubular hyperplasia) were observed to fulfill the third criterion.

###### Consideration of additional International Agency for Research on Cancer (IARC) 1999 criteria

An alpha 2u-globulin framework was published by IARC in 1999 (Capen et al., 1999). See Table 1-10 for criteria laid out in the IARC consensus document.

Table 1-10 International Agency for Research on Cancer (IARC) criteria for an agent causing kidney tumors through an alpha 2u-globulin associated response in male rats

IARC criteria (Capen et al., 1999)
- Lack of genotoxic activity (agent and/or metabolite) based on an overall evaluation of in vitro and in vivo data.; - Male rat specificity for nephropathy and renal tumorigenicity.; - Induction of the characteristic sequence of histopathological changes in shorter term studies, of which protein droplet accumulation is obligatory.; - Identification of the protein accumulating in tubule cells as alpha―alpha 2u-globulin.; - Reversible binding of the chemical or metabolite to alpha 2u-globulin.; - Induction of sustained increased cell proliferation in the renal cortex.; - Similarities in dose-response relationship of the tumor outcome with the histopathological end-points (protein droplets, alpha 2u-globulin accumulation, cell proliferation).

A few minor differences exist between the EPA and IARC criteria. The EPA framework requires the identification of several (but not necessarily all) additional steps in the histopathological sequence associated with alpha 2u-globulin nephropathy, whereas IARC requires the “induction of the characteristic sequence of histopathological changes in shorter-term studies, of which protein droplet accumulation is obligatory” but doesn’t specify which or how many of the additional histopathological changes must be observed to consider this criteria met. In addition, IARC has specific criteria pertaining to lack of genotoxicity of parent compound/metabolite and male rat specificity for nephropathy and renal tumorigenicity whereas the EPA framework considers these data as supplemental information (see Part 4, XVII B. Additional Information Useful for Analysis). Additional criteria required by IARC which are not considered essential in the EPA’s framework are discussed below.

###### Lack of genotoxic action

There are a limited number of studies available to assess the genotoxic potential of tert-butanol (see Appendix B.2.2. in Supplemental Information for further details). tert-Butanol was generally negative in a variety of genotoxicity assays and cell systems, including Salmonella typhimurium, Escherichia coli, and Neurospora crassa (McGregor et al., 2005; Zeiger et al., 1987; Dickey et al., 1949). Studies also demonstrated negative results for gene mutations, sister chromatid exchanges, micronucleus formation, and chromosomal aberrations (NTP, 1995; Mcgregor et al., 1988). However, deoxyribonucleic acid (DNA) adducts were found in male Kunming mice (Yuan et al., 2007) and DNA damage in human promyelocytic leukemia (HL-60) cells (Tang et al., 1997). In another study (Sgambato et al., 2009), an initial increase in DNA damage was observed as measured by nuclear fragmentation, but the damage reduced drastically following 4 hours of exposure and entirely disappeared after 12 hours of exposure to tert-butanol.

Overall, the evidence base is limited in terms of either the array of genotoxicity tests conducted or the number of studies within the same type of test. In addition, the results are either conflicting or inconsistent. The test strains, solvents, or control for volatility used in certain studies are variable and could influence results. Furthermore, in some studies, the specificity of the methodology used has been challenged. Given the inconsistencies and limitations of the evidence base in terms of the methodology used, number of studies in the overall evidence base, coverage of studies across the genotoxicity battery, and the quality of the studies, the weight-of-evidence analysis is inconclusive.

###### Male rat specificity for nephropathy and tumors

Kidney tumors were observed only in male rats and not in female rats or mice of either sex. Because an alpha 2u-globulin MOA is specific to male rats, the endpoints would not expected in female rats or mice of either sex and none were observed (see Table 1-2). No treatment related changes in kidney histopathology following oral or inhalation exposures were observed in male or female mice (NTP, 1997, 1995). No protein droplets, alpha 2u-globulin immunostaining, or increases in cell proliferation were observed in the kidneys of female rats, but they were seen in the male rats (Borghoff et al., 2001). Cell proliferation increased in male, but not female rats, exposed to tert-butanol via inhalation for 10 days (Borghoff et al., 2001) and via drinking water for 90 days (Lindamood et al., 1992). Increased kidney weights were observed in female rats exposed to 1,364 or 5,304 mg/m^3^ tert-butanol after 10-days (Borghoff et al., 2001); in female F344 rats exposed to 290, 590, 850, 1,560, or 3,620 mg/kg-day tert-butanol in a 13-week drinking water study (NTP, 1995); in female B6C3F1 mice exposed to 11,620 mg/kg-day tert-butanol in a 13-week drinking water study (NTP, 1995); and in female F344 rats exposed to 6,368 mg/m^3^ tert-butanol in a 13-week inhalation study (NTP, 1997). Kidney transitional epithelial hyperplasia and inflammation were observed in female F344 rats exposed to 850, 1,560, or 3,620 mg/kg-day for 13 weeks, as well as 180, 330, or 650 mg/kg-day for 2 years (NTP, 1995). Female F344 rats exposed to 850, 1,560, or 3,620 mg/kg-day tert-butanol had a dose-related increase in the incidence of nephropathy and the incidences were greater than that of controls (NTP, 1995). Female rats also had lesions associated with nephropathy (NTP, 1995), but none of the lesions were similar to those observed in the male rat, which were associated with alpha 2u-globulin nephropathy. Therefore, the results indicate that there are some kidney effects in female rats and mice, but that the characteristic changes that occur with alpha 2u-globulin accumulation are only observed in male rats. This criterion of male rat specificity is met.

###### Summary and conclusions for Question One: Is the α2u-globulin process occurring in male rats exposed to tert-butanol?

Oral exposure of tert-butanol to male F344 rats resulted in an increased incidence of renal tubule tumors in a 2-year oral bioassay (Hard et al., 2011; NTP, 1995). Several histopathological observations in exposed male rats were consistent with an alpha 2u-globulin MOA. This evidence includes the increased size and number of hyaline droplets and the accumulated alpha 2u-globulin protein in the hyaline droplets. Additionally, several subsequent steps in the histopathological sequence were observed. Overall, available data are sufficient for all three required EPA criteria, suggesting that the alpha 2u-globulin process is operative. Furthermore, the available data is sufficient to fulfill the IARC criteria for establishing the role for alpha 2u-globulin in male rats, with the exception of genotoxic potential because of a limited genotoxicity evidence base. Although the evidence indicates a role for alpha 2u-globulin accumulation in the etiology of kidney tumors induced by exposure to tert-butanol in male rats, it is plausible that tert-butanol is a weak inducer of alpha 2u-globulin considering the available histopathological observations and uncertainty regarding the temporal and dose concordance of the lesions.

###### Question Two: Are the renal effects in male rats exposed to tert-butanol due solely to the alpha 2u-globulin process?

If the alpha 2u-globulin process is operative, U.S. EPA (1991a) identified a second question that must be answered regarding whether the renal effects are due solely to the alpha 2u-globulin process, a combination of the alpha 2u-globulin process and other carcinogenic processes, or primarily due to other processes. U.S. EPA (1991a) stated that additional data can help inform whether the alpha 2u-globulin process is the sole contributor to renal tubule tumor development in male rats. These additional data are considered and discussed in detail below.

(a) Hypothesis-testing of the alpha 2u-globulin sequence of effects and structure-activity relationships that might suggest the chemical belongs in a different class of suspected carcinogens; No data are available to evaluate these considerations.

(b) Biochemical information regarding binding of the chemical to the alpha 2u-globulin protein; Williams and Borghoff (2001) reported that tert-butanol reversibly and noncovalently binds to alpha 2u-globulin in the kidneys of male rats. This provides additional support to the involvement of the alpha 2u-globulin process although EPA could not determine the relative contribution of alpha 2u-globulin to kidney tumors in male rats.

(c) Presence of sustained cell replication in the S2 (P2) segment of the renal tubule at doses used in the cancer bioassay and a dose-related increase in hyperplasia of the renal tubule; Sustained cell division in the proximal tubule of the male rat is consistent with, although not specific to, the alpha 2u-globulin process. Cell proliferation was observed in two studies [13-week, NTP (1995) and 10-day, Borghoff et al. (2001)] but whether the proliferation was compensatory is unknown because cytotoxicity was not observed in these studies. Although the data do not support sustained occurrence of cell division subsequent to cytotoxic cell death, renal tubule hyperplasia in male rats was reported after 2 years of exposure (NTP, 1995). Thus, although some evidence of sustained cell replication is available, it does not specifically support alpha 2u-globulin protein accumulation.

(d) Covalent binding to DNA or other macromolecules, suggesting another process leading to tumors andgenotoxicity (alpha 2u-globulin inducers are essentially nongenotoxic); One study (Yuan et al., 2007) reported an increase in tert-butanol-DNA adducts in the liver, kidney, and lung of mice administered a single low dose of tert-butanol (≤1 mg/kg) in saline via gavage (see Appendix B, Section B.3 in Supplemental Information for further details). An extremely sensitive method of detection was used (accelerator mass spectrometry), but the DNA adduct species were not identified, and no replication of these results has been identified in the literature. The few studies available to assess the direct genotoxic potential of tert-butanol had primarily negative results, although a few studies report DNA damage induced by oxidative stress. DNA damage induced by oxidative stress is consistent with the decreased levels of glutathione in male rat kidneys reported by Acharya et al. (1995) after 10 weeks of tert-butanol exposure. This type of genetic damage would not necessarily preclude a role for alpha 2u-globulin, but not enough information is available to determine whether oxidative stress could initiate or promote kidney tumors in concert with alpha 2u-globulin accumulation in male rat kidneys.

(e) Nephrotoxicity in the male rat not associated with the alpha 2u-globulin process or CPN, suggesting the possibility of other processes leading to renal tubule nephrotoxicity and carcinogenicity; Nephropathy reported in the 13-week oral and inhalation and 2-year oral studies was considered CPN and these effects were exacerbated by treatment with tert-butanol. At 13 weeks (NTP, 1997, 1995) and 2 years (NTP, 1995), oral and inhalation exposure increased the severity of nephropathy in male rats (NTP, 1995). Similarly, the severity of nephropathy was increased in females at 2 years, but only the incidence of nephropathy was increased in females following a 13-week oral exposure (NTP, 1995).

Increased incidences of suppurative inflammation and kidney transitional epithelial hyperplasia were observed in female rats orally exposed to tert-butanol for 2 years. NTP (1995) and Frazier et al. (2012) characterized these endpoints as associated with CPN, and an analysis of the individual animals indicates these endpoints are moderately correlated with CPN. However, most cases of suppurative inflammation and transitional epithelial hyperplasia are spontaneous changes whose cause is unknown and are typically unrelated to CPN or have been noted as secondary changes to CPN (NIEHS, 2019). At 2 years, the male rats also exhibited a dose-related increase in transitional epithelial hyperplasia, and the correlation of this endpoint with CPN was stronger than in female rats.

Kidney weights were increased in male and female rats in the 13-week oral and inhalation evaluations (NTP, 1997, 1995) and 15-month oral evaluation (NTP, 1995). The dose-related increases observed in both male and female rats suggest that the kidney-weight changes are indicative of treatment-related molecular processes primarily unrelated to alpha 2u-globulin protein accumulation. Given that CPN also was increased at these time points, however, the influence of CPN on kidney weights cannot be ruled out.

Overall, the nephrotoxicity observed in the male rat is difficult to disentangle from CPN and alpha 2u-globulin processes. The moderate correlation between CPN severity and renal tumor incidence in male rats (rho = 0.45) and the very weak correlation between renal tubule hyperplasia and renal tumors (rho = 0.16; see Table 1-8) suggest that alpha 2u-globulin nephropathy is not solely responsible for the renal tumors. Furthermore, considering that the treatment-related exacerbation of CPN severity in female rats occurs without the subsequent induction of renal tumors, this suggests that other processes besides alpha 2u-globulin and CPN in males might be responsible for the renal tubule tumors.

###### Summary and conclusions for Question Two

Although the evidence suggests that tert-butanol induces alpha 2u-globulin nephropathy, the data indicate that it is a weak inducer and the relative contribution of alpha 2u-globulin and other processes to tumors observed in male rats cannot be determined.

The lack of compensatory cell proliferation in male rats and evidence of nephrotoxicity in female rats suggest that other processes, in addition to the alpha 2u-globulin process, are operating. Furthermore, the accumulation of hyaline droplets and the induction of renal tubule hyperplasia occurred at higher doses than those inducing renal tubule tumors. Collectively, these data suggest that tert-butanol induces the alpha 2u-globulin pathway at high doses (>420 mg/kg-day), resulting in tumor formation in male rats. However, other unknown pathways that may contribute to renal tumor induction could be operative at lower doses (<420 mg/kg-day).

##### Chronic progressive nephropathy and renal carcinogenicity

Scientists disagree about the extent to which CPN can be characterized as a carcinogenic MOA suitable for analysis under EPA Cancer Guidelines (Hard et al., 2013; Melnick et al., 2013; Melnick et al., 2012). The etiology of CPN is unknown, and CPN is both a spontaneous and complex disease whose processes are affected by aging and strain specificity (NIEHS, 2019). Therefore, it is difficult to separate the effects of spontaneously occurring CPN from those effects on CPN induced by chemical exposure. Proponents of CPN as an MOA have developed an evolving series of empirical criteria for attributing renal tubule tumors to CPN. Hard and Khan (2004) proposed criteria for concluding that a chemical is associated with renal tubule tumors through an interaction with CPN. Hard et al. (2013) slightly revised and restated their criteria for considering exacerbation of CPN as an MOA for renal tubule tumors in rats. Table 1-11 lists these sets of proposed empirical criteria for attributing renal tubule tumors to CPN.

Table 1-11 Proposed empirical criteria for attributing renal tumors to chronic progressive nephropathy

Hard and Khan (2004) | Hard et al. (2013)
- First and foremost, the chemical must have been shown to exacerbate CPN to very advanced stages of severity, especially end-stage kidney disease, in comparison to control rats in a 2-yr carcinogenicity study.; - The tumors should occur in very low incidence and, for the most part, be minimal-grade lesions conforming to small adenomas or lesions borderline between atypical tubule hyperplasia (ATH) and adenoma.; - Such tumors should be associated only with the highest grades of CPN severity.; - The tumors and any precursor foci of ATH must be restricted to CPN-affected parenchyma and are usually observed only toward the end of the 2-yr studies.; - Careful microscopic examination of renal parenchyma not involved in the CPN process should reveal no evidence of compound-induced cellular injury or other changes that would suggest alternative modes of action. | - Genotoxic activity based on overall evaluation of in vitro and in vivo data is absent.; - Tumor incidence is low, usually <10%.; - Tumors are found toward the end of 2-yr studies.; - Lesions are usually ATH or adenomas (carcinomas occasionally can occur).; - Chemical exacerbates CPN to most advanced stages, including end-stage kidney disease.; - ATH and tumors occur in rats with advanced CPN and in CPN-affected tissue.; - Cytotoxicity in CPN-unaffected tubules, in rats with lower grades of CPN, and in subchronic studies is absent.

Hard et al. (2013) maintain that knowing the detailed etiology or underlying mechanism for CPN is unnecessary. Instead, identifying increased CPN with its associated increase in tubule cell proliferation as the key event is adequate. Nonetheless, Hard et al. (2013) also postulated a sequence of key events for renal tumorigenesis involving exacerbation of CPN:

- Exposure to chemical (usually at high concentrations);
- Metabolic activation (if necessary);
- Exacerbated CPN, including increased number of rats with end-stage renal disease;
- Increased tubule cell proliferation because more kidney is damaged due to CPN exacerbation;
- Hyperplasia; and
- Adenoma (infrequently carcinoma).

###### Evaluation of the mode of action (MOA) proposed by Hard et al. (2013)

Setting aside the question of whether CPN is (Hard et al., 2013; Hard and Khan, 2004) or is not (Melnick et al., 2013; Melnick et al., 2012) an MOA suitable for analysis, this section provides an analysis of the mechanistic data pertinent to CPN. EPA Cancer Guidelines (U.S. EPA, 2005b) define a framework for judging whether available data support a hypothesized MOA; the analysis in this section follows the structure presented in the cancer guidelines.

Description of the hypothesized MOA. Under the EPA framework, toxicokinetic studies are important for identifying the active agent, but toxicokinetic events per se are not key events of an MOA; specifically, chemical exposure and metabolic activation considered in Hard et al. (2013) as the first two key events were not considered in EPA’s evaluation of the proposed MOA. Thus, the EPA analysis of the MOA proposed by Hard et al. (2013) begins with (1) exacerbated CPN, including increased number of rats with end-stage renal disease, and proceeds via (2) increased tubule cell proliferation, (3) hyperplasia, and (4) adenoma, or infrequently, carcinoma.

Strength, consistency, specificity of association. The relationship between exacerbated CPN and renal tumors is moderate in male rats in the NTP (1995) study. According to the NTP (1995) analysis, the mean CPN grades (same as “severity of nephropathy” reported by NTP) presented on a scale 1-4 for male rats with renal tumors were 3.5, 3.6, 3.7, and 3.4 at doses 0, 1.25, 2.5, and 5 mg/mL, respectively. The mean CPN grades for male rats without renal tumors were 2.9, 2.8, 2.8, and 3.2 for the same dose groups. The reanalysis of the NTP data by Hard et al. (2011) yielded similar numbers. Analysis of the individual occurrence of CPN and renal tumors demonstrated a moderately positive correlation (rho = 0.43; see Table 1-8). The relationship between CPN and renal tumors, however, is neither consistent nor specific in the NTP (1995) study: No female rats developed renal tumors regardless of the presence of relatively low-grade or relatively high-grade CPN. For example, in female rats surviving more than 700 days, the mean CPN grades were 1.7 and 3.2 at doses of 0 and 10 mg/mL, respectively, but no tumors developed in either group.

Dose-response concordance. The dose-response relationships for CPN, renal tubule hyperplasia, and renal tubule tumors somewhat differ between the two analyses. According to the NTP (1995) analysis, at doses of 0, 1.25, 2.5, and 5 mg/mL, the mean CPN grades for all male rats were 3.0, 3.1, 3.1, and 3.3; the incidences of renal tubule hyperplasia (standard and extended evaluation combined) were 14/50, 20/50, 17/50, and 25/50; and the incidences of renal tubule adenomas or carcinomas were 8/50, 13/50, 19/50, and 13/50 (see Table 1-3). The reanalysis by Hard et al. (2011) reported similar tumor incidences (4/50, 13/50, 18/50, and 12/50), except that four fewer rats in the controls and one fewer rat in the group exposed to 2.5 mg/mL had tumors. The lower control incidence (4/50 vs. 14/50 in the NTP study) observed in this reanalysis accentuates the differences in these dose-response relationships. For example, the maximal tumor response (4/50 in controls vs. 18/50 at the middle dose) does not parallel the marginal change in CPN severity (i.e., group average of 3.0 to 3.1). That a marginal increase in CPN severity would be associated with significant tumor induction seems inconsistent. Furthermore, CPN severity is nearly as great in the female rats, yet no females developed tumors, as noted above.

Temporal relationship. The severity of CPN progressed over time. According to the NTP (1995) analysis, the mean CPN grades in the 13-week study of male rats were 1.0, 1.6, 2.6, 2.7, 2.6, and 1.1 at doses of 0, 2.5, 5, 10, 20, and 40 mg/mL. At the 15-month interim evaluation of the 2-year study, the mean CPN grades were 2.4, 2.8, 2.7, and 2.6 at doses of 0, 1.25, 2.5, and 5 mg/mL and, at 2 years, had increased to 3.0, 3.1, 3.1, and 3.3. Similarly, the severity of neoplastic lesions increased at the end of life. At the 15-month interim evaluation, only two rats had developed renal tubule hyperplasia and one other had a renal tubule adenoma; at 2 years, the incidences of these two lesions were much higher in all dose groups (see previous paragraph). These results are consistent with CPN as an age-related disease and with hyperplasia and tumors appearing near the end of life.

Biological plausibility and coherence. In general, the relationship between exacerbated CPN and renal tubule tumors in male rats seems plausible and coherent. Some patterns in the dose-response relationships for CPN, hyperplasia, and tumors are discrepant. Perhaps more importantly, the patterns also are discrepant for the relationships between CPN grades and renal tubule tumors in female rats. In addition, the increased incidences in renal tubule tumors in all exposed male rats exceed the 10% criterion proposed by Hard et al. (2013) (see Table 1-11), even more so when making comparisons with the lower control tumor incidence from the Hard et al. (2011) reanalysis.

###### Conclusions about the hypothesized chronic progressive nephropathy (CPN)-related mode of action (MOA)

As recommended by EPA Cancer Guidelines (U.S. EPA, 2005b), conclusions about the hypothesized MOA can be clarified by answering three questions presented below.

(a) Is the hypothesized MOA sufficiently supported in the test animals? Exacerbated CPN leading to renal tubule tumors in male rats late in life appears to have some support. Consistency is lacking, however, between males and females and in the dose-response relationships between CPN, hyperplasia, and adenomas, Melnick et al. (2012) and Melnick et al. (2013) concluded, based on an analysis of 60 NTP studies, no consistent association exists between exacerbated CPN and the incidence of renal tubule tumors in rats. Without a consistent association and an understanding of key events, the authors maintain that determining the human relevance of processes that might be occurring in rats is not possible. In an earlier analysis of 28 NTP studies, Seely et al. (2002) found a slight but statistically significant increase in CPN severity in animals with renal tubule tumors, but did not determine that this relationship is causal. They suggested that the number of tumors due to chemically exacerbated CPN would be few.

These inconsistencies make it difficult to attribute all renal tumors to either CPN or to alpha 2u-globulin-related nephropathy (see previous section on alpha 2u-globulin), raising the likelihood of another, yet unspecified MOA.

(b) Is the hypothesized MOA relevant to humans? CPN is a common and well-established constellation of age-related lesions in the kidney of rats, and no counterpart to CPN in aging humans is known (NIEHS, 2019). Scientists disagree, however, on the relevancy of the CPN MOA to humans. Hard et al. (2009) and Hard et al. (2013) cited several differences in pathology between rat CPN and human nephropathies in their arguments that CPN-related renal tumors in rats are not relevant to humans. On the other hand, Melnick et al. (2012) and Melnick et al. (2013) argued that the etiology of CPN and the mechanisms for its exacerbation by chemicals are unknown and fail to meet fundamental principles for defining an MOA and for evaluating human relevance. While the morphological spectrum observed in CPN in male rats does not have a human analogue in the aging kidney (NIEHS, 2019), these individual lesions or processes could occur in a human kidney, and their occurrence as a group in the aged rat kidney does not make each one rat-specific if a treatment effect occurs for one or more of them. Given that the etiology of CPN is unknown and the disease process is complex, it is plausible that any chemical that causes CPN in rats may have the potential to exacerbate disease processes in the human kidney (NIEHS, 2019). This issue is unresolved.

(c) Which populations or lifestages can be particularly susceptible to the hypothesized MOA? It is unknown whether certain human populations or lifestages are especially susceptible to tumors induced through exacerbated CPN.

In summary, the renal tubule tumors are partially attributed to CPN in male rats and not in female rats, considering discrepant patterns in the dose-response relationships for CPN, hyperplasia, and renal tubule tumors; the moderately strong correlation between CPN grades and renal tubule tumors in male rats; and the lack of relationships between CPN severity and renal tumors in female rats together with the lack of a generally accepted MOA for CPN.

This position can be reconciled with that of Melnick et al. (2012) and Melnick et al. (2013), who argued against dismissing renal tubule tumors in rats that can be related to exacerbated CPN. It also can be reconciled with Hard et al. (2013), who, while maintaining these tumors are not relevant to humans, also allowed that there is no generally accepted MOA for CPN akin to that for alpha 2u-globulin-related nephropathy. Hard et al. (2013) made this statement after reporting on the collective experience of national and international health agencies worldwide with the use of CPN as an MOA. Of 21 substances that exacerbated CPN and caused renal tumors, most were multisite carcinogens, and other tumor sites contributed to the evaluations. Only two assessments explicitly considered CPN as a renal tumor mechanism. One was the assessment of ethylbenzene by the German Federal Institute for Occupational Safety and Health, in which the agency concluded that the kidney tumors were associated with the high, strain-specific incidence of CPN unknown in humans [as discussed in Hard et al. (2013)]. The other was the Integrated Risk Information System (IRIS) assessment of tetrahydrofuran, for which EPA found the evidence insufficient to conclude that the kidney tumors are mediated solely by the hypothesized MOAs (U.S. EPA, 2012c). Hard et al. (2013) attributed these different conclusions to either different data for the two chemicals or the lack of a generally accepted MOA akin to alpha 2u-globulin-related nephropathy.

Relevant to this last point, IARC (1999) developed a consensus statement that listed considerations for evaluating alpha 2u-globulin-related nephropathy in rats, which was based on the work of 22 scientists, including 3 who were coauthors of Hard et al. (2013) and 2 who were coauthors of Melnick et al. (2012) and Melnick et al. (2013). A similar broad-based consensus that defines a sequence of key events for exacerbated CPN, distinguishes it more clearly from alpha 2u-globulin-related nephropathy, and evaluates its relevance to humans would be helpful in advancing the understanding of these issues.

#### Overall Conclusions on Mode of Action for Kidney Effects

tert-Butanol increases alpha 2u-globulin deposition and hyaline droplet accumulation in male rat kidneys and affects several of the subsequent steps in that pathological sequence. These data provide evidence that the alpha 2u-globulin process is operating. tert-Butanol appears to be a weak inducer of alpha 2u-globulin nephropathy, and the relative contribution of this process to renal tubule nephropathy and carcinogenicity cannot be determined with the information available. CPN and the exacerbation of CPN (likely due to both the alpha 2u-globulin process and tert-butanol exposure) play a role in renal tubule nephropathy. The available evidence indicates that CPN might be involved in the induction of renal tubule tumors in male rats, likely by providing proliferative stimulus in the form of compensatory regeneration following toxicity to the renal tubule epithelium, although these effects were not observed in some studies. Additionally, several endpoints in female rats indicate that renal tubule nephrotoxicity and increased kidney weights related to tert-butanol exposure cannot be explained by the alpha 2u-globulin process.

#### Integration of Kidney Effects

Kidney effects (increases in nephropathy, severity of nephropathy, hyaline droplets, linear mineralization, suppurative inflammation, transitional epithelial hyperplasia, mineralization, and kidney weight) were observed, predominantly in male and female rats across multiple tert-butanol studies. The available evidence indicates that multiple processes induce the noncancer kidney effects. Two endpoints in male rats (hyaline droplets, linear mineralization) are components of the alpha 2u-globulin process. U.S. EPA (1991a) states that if the alpha 2u-globulin process were occurring in male rats, the renal tubule effects associated with this process in male rats would not be relevant to humans for the purposes of hazard identification. In cases such as these, the characterization of human health hazard for noncancer kidney toxicity would rely on effects not specifically associated with the alpha 2u-globulin process in male rats.

The group of lesions generally reported as “nephropathy,” is related to CPN. CPN is a common and well-established constellation of age-related lesions in the kidney of rats; for which no known counterpart to CPN exists in aging humans, and the mode of action is unknown (NIEHS, 2019). CPN is not, inherently, a specific diagnosis but an aggregate term describing a spectrum of effects. The individual lesions associated with CPN (tubular degeneration, glomerular sclerosis, etc.) also occur in the human kidney. (Zoja et al., 2015; Gorriz and Martinez-Castelao, 2012). Thus, it cannot be ruled out that chemicals that exacerbate CPN in rats may have the potential to exacerbate disease processes in the human kidney (NIEHS, 2019).

Because female rats are not affected by alpha 2u-globulin nephropathy, lesions associated with CPN in female rats are informative for human hazard characterization. Several other noncancer endpoints resulted from tert-butanol exposure and are appropriate for consideration of a kidney hazard, specifically: suppurative inflammation in female rats, transitional epithelial hyperplasia in female rats, severity of nephropathy in female rats, incidence of nephropathy in female rats, and increased kidney weights in rats but not mice. Based on dose-related increases in these noncancer endpoints in rats, kidney effects are a potential human hazard of tert-butanol exposure. The hazard and dose-response conclusions regarding these noncancer endpoints associated with tert-butanol exposure are discussed further in Section 1.3.1.

The carcinogenic effects observed following tert-butanol exposure include increased incidences of renal tubule hyperplasia (considered a preneoplastic effect) and tumors in male rats. EPA concluded that the three criteria were met to indicate that an alpha 2u-globulin process is operating. Because renal tubule tumors in male rats did not arise solely from the alpha 2u-globulin and CPN processes and because some of the tumors are attributable to other carcinogenic processes, such tumors remains relevant for purposes of hazard identification (U.S. EPA, 1991a).^10^ The hazard and dose-response conclusions regarding the renal tubule hyperplasia and tumors associated with tert-butanol exposure are further discussed as part of the overall weight of evidence for carcinogenicity in Section 1.3.2.

### 1.2.2 Thyroid Effects

#### Synthesis of Effects in the Thyroid

The evidence base on thyroid effects following tert-butanol exposure contains no human data, two oral subchronic and two oral chronic studies [one of each duration in rats and in mice; NTP (1995)], and two inhalation subchronic studies [one in rats and one in mice; NTP (1997)]. Studies employing short-term and acute exposures that examined thyroid effects are not included in the evidence table. These studies are discussed, however, in the text if they provide data informative of MOA or hazard identification. No gross thyroid effects were reported in the 13-week evaluations of mice or rats following oral or inhalation exposure (NTP, 1997, 1995), and therefore, subchronic studies were not included in the evidence table. The two available chronic studies are arranged in the evidence table by effect and then by species (see Table 1-12 and Figure 1-10).

Thyroid effects, specifically follicular cell hyperplasia and adenomas, were observed in mice of both sexes after 2 years of oral exposure via drinking water (NTP, 1995). NTP (1995) noted, “[p]roliferation of thyroid gland follicular cells is generally considered to follow a progression from hyperplasia to adenoma and carcinoma.” Both male and female mice exhibited a dose-related increase in the incidence of hyperplasia, and the average severity across all dose groups was minimal to mild with scores ranging from 1.2 to 2.2 (out of 4). Increased incidence of adenomas also was observed in the tert-butanol-treated female mice at the high dose, with the only carcinoma observed in high-dose males. At the highest dose, mean body weights of female mice were 10 to 15% lower than control animals from Week 13 to the end of the study, with a final average body-weight reduction of 12% raising some question that the thyroid tumors were the result of excessive toxicity in female mice rather than carcinogenicity of tert-butanol. EPA Cancer Guidelines (U.S. EPA, 2005a) discusses the determination of an “excessively high dose” as compared to an “adequate high dose” and describes the process as one of expert judgment which requires that “…adequate data demonstrate that the effects are solely the result of excessive toxicity rather than the carcinogenicity of the tested agent” (U.S. EPA, 2005a). In the 2-year oral bioassay (NTP, 1995), study authors noted that water consumption by exposed females was similar to controls and that no overt toxicity was observed. Furthermore, female mice in the high-dose group had higher rates of survival than did the control animals. No treatment-related thyroid effects were reported in rats of either sex following 2 years of oral exposure (NTP, 1995).

The tumor response in male mice, adjusted for early mortality, showed a statistically significant increasing trend (Cochran-Armitage trend test, p = 0.041; analysis performed by EPA). Although the response appeared nonmonotonic, with a slightly lower response at the high-dose level than at the mid-dose level, the increased mortality reported in the high-dose group occurred before tumors appeared; about 40% of the high-dose males died before the first tumor (a carcinoma) appeared in this group at Week 83. By comparison, only ~10% of the control group had died by this time, and the single tumor in the control group was observed at study termination. Mortality in the exposed female mice was similar to controls.

Table 1-12 Evidence pertaining to thyroid effects in animals following oral exposure to tert-butanol

Reference and study design | Results
Follicular cell hyperplasia
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Incidence^b^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Male | | Female
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Dose (mg/kg-d) | Follicular cell hyperplasia | Dose (mg/kg-d) | Follicular cell hyperplasia
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 0 | 3/50 | 0 | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 90 | 0/49 | 180 | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 200 | 0/50 | 330 | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 420^a^ | 0/50 | 650^a^ | 0/50
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Incidence (severity)
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Male | | Female
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Dose (mg/kg-d) | Follicular cell hyperplasia | Dose (mg/kg-d) | Follicular cell hyperplasia
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 0 | 5/60 (1.2) | 0 | 19/58 (1.8)
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 540 | 18/59^c^ (1.6) | 510 | 28/60 (1.9)
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 1,040 | 15/59^c^ (1.4) | 1,020 | 33/59^c^ (1.7)
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 2,070^a^ | 18/57^c^ (2.1) | 2,110 | 47/59^c^ (2.2)
Follicular cell tumors
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Incidence^b^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Dose (mg/kg-d) | Follicular cell adenoma | | Follicular cell carcinoma
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Male
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 0 | 2/50 | | 2/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 90 | 0/49 | | 0/49
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 200 | 0/50 | | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 420^a^ | 0/50 | | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Female
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 0 | 1/50 | | 1/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 180 | 0/50 | | 0/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 330 | 1/50 | | 1/50
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 650^a^ | 0/50 | | 0/50
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Incidence
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Dose (mg/kg-d) | Follicular cell adenoma | Follicular cell carcinoma | Follicular cell adenoma or carcinoma (mortality adjusted rates)^d,e^ | Animals surviving to study termination
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Male
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 0 | 1/60 | 0/60 | 1/60 (3.6%) | 27/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 540 | 0/59 | 0/59 | 0/59 (0.0%) | 36/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 1,040 | 4/59 | 0/59 | 4/59 (10.1%) | 34/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 2,070^a^ | 1/57 | 1/57 | 2/57 (8.7%) | 17/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Female
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 0 | 2/58 | 0/58 | 2/58 (5.6%) | 36/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 510 | 3/60 | 0/60 | 3/60 (8.6%) | 35/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 1,020 | 2/59 | 0/59 | 2/59 (4.9%) | 41/60
NTP (1995); B6C3F1 mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 2,110 | 9/59^c^ | 0/59 | 9/59^c^ (19.6%) | 42/60

a Survival in the high-dose group significantly decreased.

b Results do not include the animals sacrificed at 15 mo.

c Statistically significant p ≤ 0.05 as determined by the study authors.

d Mortality-adjusted rates were not calculated by the study authors for follicular cell carcinoma. The mortality-adjusted rates for the incidence of adenomas are the same as the combined rates, with the exception of the male high-dose group, in which the rate for adenomas alone was 5.9%.

e Cochran-Armitage trend test was applied to mortality-adjusted thyroid tumor incidences, by applying the NTP adjusted rates to the observed numbers of tumors to estimate the effective number at risk in each group. For male mice, p = 0.041; for female mice, p = 0.028.

Note: Conversions from drinking water concentrations to mg/kg-d were performed by the study authors.

Figure 1-10 Exposure-response array of thyroid follicular cell effects following chronic oral exposure to tert-butanol

(Note: Only one carcinoma was observed in male mice in the high-dose group.)

Source: NTP (1995).

#### Mode of Action Analysis—Thyroid Effects

Few studies have examined the MOA responsible for tert-butanol-induced thyroid effects. One hypothesis is that tert-butanol increases liver metabolism of thyroid hormones, triggering a compensatory increase in pituitary thyroid-stimulating hormone (TSH) production. Such sustained increases in TSH could induce elevated thyroid follicular cell proliferation and hyperplasia and lead to follicular cell adenoma and carcinoma. This enhancement of liver metabolism and excretion of thyroid hormones is one of several potential antithyroid MOAs identified in EPA’s guidance on the assessment of thyroid follicular cell tumors (U.S. EPA, 1998a).

To determine whether the thyroid follicular cell tumors result from a chemically induced antithyroid MOA, U.S. EPA (1998a) requires that the available evidence base demonstrate (1) increases in thyroid cell growth, (2) thyroid and pituitary hormone changes consistent with the antithyroid MOA, (3) site(s) of the antithyroid action, (4) dose correlation among the various effects, and (5) reversibility of effects in the early stages of disruption. In addition, another critical element is the determination of the mutagenic potential. The available evidence for each of these aspects of antithyroid activity following tert-butanol exposure is discussed below.

##### 1) Increases in cell growth (required)

U.S. EPA (1998a) considers increased absolute or relative thyroid weights, histological indicators of cellular hypertrophy and hyperplasia, DNA labeling, and other measurements (e.g., Ki-67 or proliferating cell nuclear antigen expression) to be indicators of increased cell growth. Only a few studies (NTP, 1997, 1995) have evaluated the thyroid by routine histological examination following tert-butanol exposure, and none have investigated specific molecular endpoints. None of the available long-term studies measured thyroid weight in mice, likely due to the technical limitations involved, and no thyroid effects were attributed to tert-butanol exposure in rats treated up to 2 years (NTP, 1997, 1995). Given the mouse findings above (NTP, 1995), the absence of treatment-related thyroid effects in rats is unusual, as chemically induced thyroid tumorigenesis is observed more frequently in rats than in mice (Hurley, 1998; U.S. EPA, 1998a). Although the short-term female mouse study by Blanck et al. (2010) stated that thyroids were weighed, no results were reported.

An increase in thyroid follicular cell hyperplasia was observed in both female and male mice after a 2-year drinking water exposure to tert-butanol (NTP, 1995). The increase was dose dependent in female mice, with a slight increase in severity in the highest dose, while male mice experienced a similar magnitude of hyperplasia induction at all doses evaluated, with increased severity at the highest dose (NTP, 1995). Thyroid follicular cell hyperplasia was not observed in any mouse study with less than 2 years of exposure: No treatment-related histological alterations in the thyroid of tert-butanol-treated (2 or 20 mg/mL) female mice after 3 or 14 days of drinking water exposure (Blanck et al., 2010) were reported, in male or female mice after 13 weeks of drinking water exposure (NTP, 1995), or in male or female mice following 18-day or 13-week inhalation studies (NTP, 1997). The observation of increased hyperplasia in male and female mice after 2 years of exposure is sufficient evidence to support increased thyroid cell growth.

##### 2) Changes in thyroid and relevant pituitary hormones (required)

Evidence of hormonal changes, including decreases in triiodothyronine (T3) and thyroxine (T4) and increases in TSH, are required to demonstrate a disruption in the thyroid-pituitary signaling axis (U.S. EPA, 1998a). Blanck et al. (2010) evaluated serum thyroid hormones in mice after 3 or 14 days of exposure to tert-butanol. No tert-butanol-related effects were observed in T3, T4, or TSH levels after 3 days. Although both T3 and T4 levels were significantly decreased by approximately 10-20% after 14 days of treatment with tert-butanol, TSH levels remained unaffected. Similar results were reported with the positive control (phenobarbital). The limited evidence available from this single study suggests that although T3 and T4 levels were decreased after 14 days, this perturbation likely did not exceed the range of homeostatic regulation in female B6C3F1 mice and thus was not likely to induce compensatory thyroid follicular cell proliferation. Multiple lines of evidence support this observation: (1) TSH levels were unaffected, indicating that the decrease in T3 and T4 levels was not severe enough to stimulate increased TSH secretion by the pituitary in this time frame; (2) thyroid hyperplasia was not induced in this study, or any others exposing mice to similar or greater concentrations for 2.5-13 weeks, suggesting that thyroid proliferation was either not induced by the hormone fluctuations or that any follicular cell proliferation during this period was too slight to be detected by routine histopathological examination; and (3) the maximal decrease in T3 or T4 hormone levels induced by tert-butanol exposure after 14 days (i.e., ~20%) was well within the range of fluctuation in T3 and T4 hormone levels reported to occur between the 3- and 14-day control groups [15-40%; Blanck et al. (2010)]. Although the study authors later attributed the lower T3 and T4 levels following tert-butanol exposure to an increase in liver metabolism (see next section), these changes could, alternatively, be due to a variety of other possible, yet uninvestigated, molecular interactions with tert-butanol. Such interactions might include (1) inhibition of iodide transport into thyroid follicular cells, (2) thyroid peroxidase inhibition, (3) thyroid follicular cell dysfunction leading to inhibition of thyroid hormone production or release, or (4) inhibition of 5’-monodeiondinase (Hurley, 1998; U.S. EPA, 1998a).

The absence of information regarding thyroid hormone levels in male mice and lack of molecular studies evaluating exposures >2 weeks in female mice are significant deficiencies in the available evidence base. Together, although small decreases in some thyroid hormone levels have been reported in female mice, the available evidence is inadequate to determine whether tert-butanol negatively affects the pituitary-thyroid signaling axis in female mice; furthermore, no evidence was available to evaluate this effect in male mice.

##### 3) Site(s) of antithyroid action (required)

The thyroid and liver are two of several potential sites of antithyroid action, with the liver the most common because increased microsomal enzyme activity there could enhance thyroid hormone metabolism and removal (U.S. EPA, 1998a). Rats are thought to be more sensitive than mice to this aspect of antithyroid activity (Roques et al., 2013; Qatanani et al., 2005; U.S. EPA, 1998a): however, rats exposed to tert-butanol for 2 years exhibited no treatment-related thyroid effects, while mice did. Typically, chronic induction of liver microsomal enzyme activity resulting from repeated chemical exposure would manifest some manner of liver histopathology, such as hepatocellular hypertrophy or hyperplasia (U.S. EPA, 1998a; NTP, 1995). In a 14-day mechanistic investigation, tert-butanol had no effect on liver weight when compared with the control group, but centrilobular hepatocellular hypertrophy was reported in 2/5 livers from high-dose mice versus 0/6 in control and 0/5 in low-dose mice (Blanck et al., 2010). Relative liver weights increased in male and female mice after 13 weeks of oral exposure (NTP, 1995) to higher doses than those evaluated by Blanck et al. (2010), although absolute liver-weight measurements in treated animals showed little change from controls suggesting that the relative measures could have been related to decreases in body weight rather than specific liver effects. Relative (and absolute) liver weights were increased in female mice (only) after 13 weeks of inhalation exposure at the two highest concentrations (NTP, 1997); liver weight was not reported in mice orally exposed for 2 years (NTP, 1995). No increase in mouse hepatocellular hypertrophic or hyperplastic histopathology was reported following 2.5 weeks to 2 years of exposure (NTP, 1997, 1995). In fact, the only liver pathology associated with tert-butanol exposure in either rats or mice from these studies was an increase in fatty liver in male mice in the high-dose group after 2 years of oral exposure (NTP, 1995). Although increased fatty liver could indicate some nonspecific metabolic alteration, the absence of a similar treatment-related effect in livers from female mice, which were sensitive to both thyroid follicular cell hyperplasia and tumor induction, suggests that it might not be related to the thyroid tumorigenesis.

One study evaluated liver enzyme expression and found highly dose-responsive induction of a single phase I cytochrome p450 (CYP450) enzyme (CYP2B10) following 14 days of tert-butanol exposure in female mice, with much smaller increases in the expression of another phase I enzyme, CYP2B9, and the phase II thyroid hormone-metabolizing enzyme, sulfotransferase 1A1 [SULT1A1; Blanck et al. (2010)]. CYP2B enzyme induction is commonly used as an indication of constitutive androstane receptor (CAR) activation; CAR can induce expression of a wide range of hepatic enzymes, including several CYPs along with thyroid hormone-metabolizing sulfotransferases (Roques et al., 2013). The only thyroid hormone-metabolizing enzyme induced by tert-butanol, however, was SULT1A1, which has been reported to be inducible in a CAR-independent manner in mice (Qatanani et al., 2005). Based on alterations in hepatic phase I and phase II enzyme activities and gene expression, the above data suggest a possible role for increased thyroid hormone clearance in the liver following repeated tert-butanol exposure; however, the expression changes in these few enzymes are not supported by any liver histopathological effects in mice exposed for longer durations, so whether this enzyme induction is transient, or simply insufficient to induce liver pathology after >2 weeks of exposure, is unknown. As noted above, no evidence is available to evaluate the potential for intrathyroidal or any other extrahepatic effects in female mice or for any of these molecular endpoints in male mice; therefore, the available evidence is inadequate to determine whether major site(s) of antithyroid action are affected.

##### 4) Dose correlation (required)

Confidence in the disruption of the thyroid-pituitary function is enhanced when dose correlation is present among the hormone levels producing various changes in thyroid histopathology, including thyroid tumors (U.S. EPA, 1998a). Furthermore, if thyroid hormone levels were affected by liver enzyme induction, confidence would be increased by a concordance among liver effects, thyroid hormone levels, and thyroid pathology. Thyroid hormone levels were evaluated only in female mice exposed to tert-butanol; after 2 weeks of exposure, both T3 and T4 were decreased with both doses (2 and 20 mg/L), and TSH was unaffected at either dose (Blanck et al., 2010). Liver expression of CYP2B10 was increased in a dose-responsive manner, while SULT1A1 messenger ribonucleic acid (mRNA) was induced by 20-30% at both doses (Blanck et al., 2010). As described above, induction of liver microsomal enzyme activity would manifest some manner of liver histopathology (Maronpot et al., 2010; U.S. EPA, 1998a; NTP, 1995), and consistent with this expected association, centrilobular hepatocellular hypertrophy was reported in 2/5 high-dose mice exposed for 2 weeks (Blanck et al., 2010). No liver histopathology, however, was attributed to tert-butanol exposure in female mice exposed for 2.5 weeks to 2 years to comparable tert-butanol concentrations (NTP, 1997, 1995). Although liver enzyme levels and activity were not specifically evaluated following subchronic to chronic exposure, the lack of liver pathology suggests a comparable lack of enzyme induction. Conversely, no histopathological alterations were reported in the thyroids of female mice after 2 weeks of oral exposure at doses that elevated some liver enzyme levels (Blanck et al., 2010).

Following 2 years of oral exposure, both follicular cell hyperplasia and follicular cell tumor incidence were increased in mice, despite a lack of treatment-related liver pathology (NTP, 1995). Any associations relating hormone changes to thyroid pathology or liver enzyme induction are limited because of the inadequate evidence base (described above); the available evidence suggests little concordance among reports of liver, pituitary, and thyroid effects in female mice, and no evidence was available to evaluate these associations in male mice.

##### 5) Reversibility (required)

Chemicals acting via an antithyroid MOA have effects (e.g., increased TSH levels, thyroid follicular cell proliferation) that are reversible after cessation of treatment (U.S. EPA, 1998a). Although increased TSH levels have not been demonstrated following tert-butanol exposure, thyroid follicular cell proliferation was observed following chronic exposure. Because no studies have evaluated changes in thyroid hormones or thyroid histopathology after cessation of tert-butanol treatment, the available evidence is inadequate to evaluate reversibility of these effects.

In summary, the available evidence base sufficiently supports only (1)—increases in thyroid cell growth. The existing data are inadequate to evaluate (2) thyroid and pituitary hormone changes consistent with the antithyroid MOA, (3) site(s) of the antithyroid action, or (4) reversibility of effects in the early stages of disruption. Although these inadequacies also limit the evaluation of (5) dose correlation among the various effects, the available evidence suggests that little correlation exists among reported thyroid, pituitary, and liver endpoints. An additional consideration is the evaluation of genotoxic potential. As summarized in Appendix B, there is limited evidence to suggest that thyroid tumors following tert-butanol exposure are due to mutagenic changes. Together, the evidence base is inadequate to determine whether an antithyroid MOA is operating in mice. In the absence of information to indicate otherwise, the thyroid tumors observed in mice are considered relevant to humans.

#### Integration of Thyroid Effects

The thyroid endpoints reported following chronic exposure to tert-butanol include increases in follicular cell hyperplasia and tumors in male and female mice. As discussed above, due to inadequacies in four of the five required areas (U.S. EPA, 1998a), the evidence is inadequate to determine whether an antithyroid MOA is operating in mice; therefore, the MOA(s) for thyroid tumorigenesis has not been identified. EPA considers the thyroid follicular cell hyperplasia to be an early event in the neoplastic progression of thyroid follicular cell tumors, and no other noncancer effects on the thyroid were observed. Thus, the hazard and dose-response conclusions regarding the thyroid follicular cell hyperplasia and tumors associated with tert-butanol exposure are discussed as part of the overall weight of evidence for carcinogenicity in Section 1.3.2.

### 1.2.3 Developmental Effects

#### Synthesis of Effects Related to Development

Four studies evaluated developmental effects [three oral or inhalation developmental studies (Faulkner et al., 1989; Nelson et al., 1989; Daniel and Evans, 1982) and a one-generation, oral reproductive study (Huntingdon Life Sciences, 2004)] in animals exposed to tert-butanol via liquid diet (i.e., maltose/dextrin), oral gavage, or inhalation. No developmental epidemiological studies are available for tert-butanol. The animal studies are arranged in the evidence tables by species, strain, and route of exposure. The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment. Two studies, however, were considered less informative: (1) Faulkner et al. (1989), because it did not provide sufficient information on the dams to determine if fetal effects occurred due to maternal toxicity and (2) Daniel and Evans (1982) due to the use of individual data instead of litter means as the statistical unit of analysis.

Developmental effects of tert-butanol observed after oral exposure (liquid diets or gavage) in several mouse strains and one rat strain include measures of embryo-fetal loss or viability (e.g., increased number of resorptions, decreased numbers of neonates per litter) and decreased fetal body weight (Huntingdon Life Sciences, 2004; Faulkner et al., 1989; Daniel and Evans, 1982). Daniel and Evans (1982) observed decreases in pup body-weight gain during postnatal days (PNDs) 2–10: however, the data suggest that this effect might be due to altered maternal behavior or nutritional status. In addition, a single-dose study reported a small increase in the incidence of variations of the skull or sternebrae in two mouse strains (Faulkner et al., 1989). Although variations in skeletal development were noted in the study, no malformations were reported. Similar developmental effects were observed after whole-body inhalation exposure in Sprague-Dawley rats for 7 hours/day on gestation days (GDs) 1–19 (Nelson et al., 1989). Fetal effects included dose-related reductions in body weight in male and female fetuses and a higher incidence of skeletal variations when analyzed based on individual fetuses (but not on a per litter basis).

In these studies, fetal effects were generally observed at high doses that cause toxicity in the dams as measured by clinical signs (e.g., decreased [~7–36%] body-weight gain and food consumption and reported ataxia and lethargy; see Table 1-13; Figure 1-11; Figure 1-12). As stated in the Guidelines for Developmental Toxicity Risk Assessment (U.S. EPA, 1991b), “an integrated evaluation must be performed considering all maternal and developmental endpoints….[W]hen adverse developmental effects are produced only at doses that cause minimal maternal toxicity; in these cases, the developmental effects are still considered to represent developmental toxicity and should not be discounted.” Although, at doses of “excessive maternal toxicity…information on developmental effects may be difficult to interpret and of limited value.” In considering the observed fetal and maternal toxicity data following tert-butanol exposure and the severity of the maternal effects, the role of maternal toxicity in the developmental effects observed at the doses used remains unclear. Specifically, discerning from the available data whether the fetal effects are directly related to tert-butanol treatment or are secondary to maternal toxicity is not possible.

Table 1-13 Evidence pertaining to developmental effects in animals following exposure to tert-butanol

Reference and study design | Results
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; F0 males: 9 wk beginning 4 wk prior to mating; F0 females: 4 wk prior to mating through PND 21; F1 males and females: 7 wk (throughout gestation and lactation; 1 male and 1 female from each litter were dosed directly from PND 21–28) | Response relative to control
| Maternal effects
| Percentage change compared to control:
| Dose (mg/kg-d) | Body-weight gain GD 0–20 | Food consumption GD 0–20 | Body-weight gain PND 1–21 | Food consumption LD 1–14 | Live pups/litter response
| 0 | – | – | – | – | –
| 64 | −3 | 0 | 3 | −2 | −9
| 160 | −4 | 0 | −10 | −6 | −11
| 400 | 0 | 4 | 3 | 0 | −7
| 1,000 | −16^a^ | 0 | 100^a,b^ | −16 | −33^a^
| Dams dosed with 400 or 1,000 mg/kg-d showed CNS effects (e.g., ataxia, lethargy) that were undetectable by 4 wk of exposure in animals exposed to 400 mg/kg-d but not those in the higher dose group
| F1 effects
| Dose (mg/kg-d) | Viability index (pup survival to PND 4) | Lactation index (pup survival to PND 21) | Sex ratio (% males) | Pup weight/litter PND 1 relative to control (%) | Pup weight PND 28 relative to control (%)
| Dose (mg/kg-d) | Viability index (pup survival to PND 4) | Lactation index (pup survival to PND 21) | Sex ratio (% males) | Pup weight/litter PND 1 relative to control (%) | Male | Female
| 0 | 96.4 | 100 | 54.4 | – | – | –
| 64 | 98.7 | 100 | 52.3 | 6 | 2 | 0
| 160 | 98.2 | 100 | 50.9 | 4 | 0 | −4
| 400 | 99.4 | 99.2 | 53.5 | 7 | 0 | −2
| 1,000 | 74.1^a^ | 98.8 | 52.1 | −10 | −12^a^ | −8
Daniel and Evans (1982); Swiss Webster (Cox) mouse; 15 pregnant dams/treatment; Liquid diet (0, 0.5, 0.75, or 1.0%, w/v); 0 (isocaloric amounts of maltose/dextrin), 3,324, 4,879, or 6,677 mg/kg-d; GD 6–20 | No statistical analysis was conducted on any of these data.
| Maternal
| Percentage change compared to control:
| Dose (mg/kg-d) | | Food consumption (mean g/animal/d) | | Body-weight gain | Number of litters (% pregnant dams)
| 0 | | – | | – | 11 (77%)
| 3,324 | | 2 | | −3 | 12 (80%)
| 4,879 | | −3 | | −19 | 8 (53%)
| 6,677 | | −4 | | −20 | 7 (47%)
| Authors note that lower food consumption in higher tert-butanol dose groups reflects problems with pair feeding and maternal sedation.
| Fetal
| Percentage change compared to control:
| Dose (mg/kg-d) | | Number of neonates/litter | | Fetal body weight on PND 2
| 0 | | – | | –
| 3,324 | | −1 | | −7
| 4,879 | | −29 | | −19
| 6,677 | | −49 | | −38
| Number of stillborn also increased with dose (3, 6, 14, and 20, respectively), but the number of stillborn per litter was not provided. The high dose also caused a delay in eye opening and a lag in weight gain during PND 2–10 (information was provided only in text or figures).
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Maternal results not reported.
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Fetal
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Dose (mg/kg-d) | | Resorptions/litter | Live fetuses/litter | Fetal weight | Sternebral variations | Skull variations
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | 0 | | – | – | – | 4/28 | 1/28
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | 1,556 | | 118^a^ | −41^a^ | −4 | 7/30 | 3/30
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Sternebral variations: misaligned or unossified sternebrae.; Skull variations: moderate reduction in ossification of supraoccipital bone.
Faulkner et al. (1989); CBA/J mouse; 7 pregnant females in control, 12 pregnant females in treated; Gavage (10.5 mmoles/kg twice a day);; 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Number of total resorptions (10 resorptions/66 implants in controls, 37/94 implants in treated) increased (p < 0.05).
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Maternal results not reported.
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Fetal
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Dose (mg/kg-d) | | Resorptions/litter | Live fetuses/litter | Fetal weight | Sternebral variations | Skull variations
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | 0 | | – | – | – | 5/21 | 1/21
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | 1,556 | | 428^a^ | −58^a^ | −4 | 9/16 | 7/16
Faulkner et al. (1989); C57BL/6J mouse; 5 pregnant females in controls, 9 pregnant females treated; Gavage (10.5 mmoles/kg twice a day); 0 (tap water) or 1,556 mg/kg-d; GD 6–18 | Sternebral variations: misaligned or unossified sternebrae.; Skull variations: moderate reduction in ossification of supraoccipital bone.; Number of total resorptions (4 resorptions/44 implants in controls, 38/68 implants in treated) increased (p < 0.05).
Nelson et al. (1989); Sprague-Dawley rat; 15 pregnant dams/treatment; Inhalation analytical concentration: 0, 2,200, 3,510, or 5,030 ppm (0, 6,669, 10,640, or 15,248 mg/m^3^), dynamic whole-body chamber 7 h/d; GD 1–19 | Maternal: Unsteady gait (no statistical tests reported), dose-dependent ↓ in body-weight gain (results presented in figure only), dose-dependent ↓ in food consumption ranging from 7 to 36%, depending on dose and time.
| Fetal
| Percentage change compared to control (mean ± standard error):
| Dose (mg/m^3^) | | Number of live fetuses/litter | | | Resorptions per litter
| 0 | | −(13 ± 2) | | | −(1.1 ± 1.2)
| 6,669 | | 0 (13 ± 4) | | | 9 (1.2 ± 1.1)
| 10,640 | | 15 (15 ± 2) | | | −18 (0.9 ± 1.0)
| 15,248 | | 8 (14 ± 2) | | | 0 (1.1 ± 0.9)
| Dose (mg/m^3^) | | Fetal weight (males) | Fetal weight (females) | | Skeletal variation by litter | Skeletal variation by fetus
| 0 | | – | – | | 10/15 | 18/96
| 6,669 | | −9^a^ | −9^a^ | | 14/17 | 35/104
| 10,640 | | −12^a^ | −13^a^ | | 14/14 | 53/103^a^
| 15,248 | | −32^a^ | −31^a^ | | 12/12 | 76/83^a^
| Skeletal variation by litter refers to the number of variations observed in the number of litters examined. Skeletal variation by fetus refers to the number of variations observed in the total number of fetuses examined. Fetuses are not categorized by litter.

CNS = central nervous system; w/v = weight by volume.

a Statistically significant p ≤ 0.05, as determined by the study authors. Conversions from diet concentrations to mg/kg-d were performed by the study authors. Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

b Large body weight gain from PND 1–21 was noted by study authors, who stated that during the first 2 weeks of lactation “F_0_ dams showed reduced feed consumption, but then in late lactation they showed weight gain instead of the more usual slight weight loss, a pattern of effects that suggested deficient lactation.”

Note: Percentage change compared to control = [(treated value − control value) ÷ control value] × 100.

Figure 1-11 Exposure-response array of developmental effects following oral exposure to tert-butanol

*The study authors did not conduct statistical analysis on these endpoints, but EPA has determined the results to be biologically significant.

Sources: (A) Daniel and Evans (1982); (B) Faulkner et al. (1989); (C) Huntingdon Life Sciences (2004).

Figure 1-12 Exposure-response array of developmental effects following inhalation exposure to tert-butanol

#### Mechanistic Evidence

No mechanistic evidence for developmental effects was identified by the literature search.

#### Integration of Developmental Effects

Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify selective developmental effects as a potential human health hazard of tert-butanol exposure. Exposure to tert-butanol during gestation resulted in increased fetal loss, decreased fetal body weight, and increases in skeletal variations in exposed offspring. Dams, however, had body-weight losses or gains (or both), decreased food consumption, and clinical signs of intoxication at the same doses of tert-butanol causing fetal effects. Therefore, determining whether tert-butanol exposure results in specific developmental toxicity or the fetal effects are due to maternal toxicity is difficult, if not impossible, from the available data. However, selective developmental toxicity of tert-butanol at the higher doses examined cannot be ruled out. Furthermore, no adverse effects were reported in one- and two-generation reproductive/developmental studies on ETBE (Gaoua, 2004a, b), further supporting the lack of evidence for developmental effects as possible human hazards following tert-butanol exposure.

### 1.2.4 Neurodevelopmental Effects

#### Synthesis of Effects Related to Neurodevelopment

Three studies evaluated neurodevelopmental effects [one in female mice, one in male rats, one in female rats; Nelson et al. (1991); Daniel and Evans (1982)] following tert-butanol exposure via liquid diet (maltose/dextrin) or inhalation. No epidemiological studies on neurodevelopment are available. The animal studies evaluating neurodevelopmental effects of tert-butanol contain study design limitations. The Daniel and Evans (1982) study had few animals per treatment group, lacked comparison of treatment-related effects to controls for all endpoints investigated, and performed no long-term neurodevelopmental testing. Further, animals in this study had lower dietary intake than the ad libitum control animals. The authors addressed this issue with a pair-fed experimental design, but a slight decrease in maternal dietary intake remained. This decrease was likely due to difficulties in the pair feeding or increased maternal sedation (Daniel and Evans, 1982). The two studies by Nelson et al. (1991) evaluated neurodevelopmental effects after either paternal or maternal exposure but did not run the exposures concurrently. The studies are arranged in the evidence tables by species and sex.

Various neurodevelopmental effects have been observed in the available studies. Effects include changes in rotarod performance following oral or inhalation exposures, decreases in open field behavior and cliff avoidance following oral exposure, and reduced time hanging on wire after inhalation exposure during gestation (see Table 1-14).

##### Rotarod performance

Inconsistent results were observed across exposure routes and species. Although Daniel and Evans (1982) found decreased rotarod performance in mouse pups of dams orally exposed during gestation, Nelson et al. (1991) observed an increase in rotarod performance in rat pups of dams exposed via inhalation during gestation.

##### Neurochemical measurements

Biochemical or physiological changes in the brain of offspring exposed during gestation or early in the postnatal period were examined only in the Nelson et al. (1991) study. The authors reported statistically significant changes in neurochemical measurements (norepinephrine, met-enkephalin, β-endorphin, serotonin) in the brain in offspring of both dams exposed via inhalation during gestation and treated adult males mated with untreated dams. The strength of these results is compromised, however, because the two concentrations tested (in both experiments) were not run concurrently, and only the data on statistically significant effects were reported. Therefore, comparison across doses or trend analysis for the effects is not feasible.

##### Physiological and psychomotor development

Daniel and Evans (1982) cross-fostered half the mouse pups born to treated mothers with untreated surrogate females to test the effects of maternal nutrition and behavioral factors on pup physiological and psychomotor development. The results indicated that pups fostered to control dams performed significantly better than those maintained with treated dams [see Table 1-14; Daniel and Evans (1982)]. These data suggest that neurodevelopmental effects were not solely due to in utero exposure to tert-butanol (Daniel and Evans, 1982). Interpretation of these results is limited, however, because the neurodevelopmental data were presented only in figures and could not be compared with controls.

Table 1-14 Evidence pertaining to neurodevelopmental effects in animals following exposure to tert-butanol

Reference and study design | Results
Daniel and Evans (1982); Swiss Webster (Cox) mouse; 15 pregnant dams/treatment (3 or 4 dams/treatment group for neurodevelopmental endpoints); Liquid diet (0, 0.5, 0.75, or 1.0%, w/v); GD 6–20; after birth, half the pups were nursed with their treated dams and the other half were fostered by untreated dams who recently gave birth; 0 (isocaloric amounts of maltose/dextrin), 3,324, 4,879, or 6,677 mg/kg-d | - A dose-dependent increase in righting reflex time, with more time needed in animals maintained with maternal dams.; - A dose-dependent decrease in open field behavior, with less activity in pups maintained with maternal dams.; - A dose-dependent decrease in rotarod performance with the pups from maternal dams having lower performances.; - A dose-dependent decrease in the amount of time the pups were able to avoid a cliff, with animals maintained with their maternal dams having less avoidance time.
Nelson et al. (1991); Sprague-Dawley rat; 15 pregnant dams/treatment (no. of litters born not reported); Inhalation analytical concentration: 0, 6,000, or 12,000 mg/m^3^; dynamic whole-body chamber 7 h/d; GD 1–19 | Data were not presented specifically by dose nor were any tables or figures of the data provided.; Maternal toxicity was noted by decreased food consumption and body-weight gains.; Results in offspring:; - Increase in rotarod performance in high-dose group (16 vs. 26 revolutions/min for the control and 12,000 mg/m^3^ animals, respectively).^a^; - Decreased time held on wire in the performance ascent test in the low-dose group (16 vs. 10 sec for the control and 6,000 mg/m^3^ animals, respectively).^a^; - For the high-dose group, no effects were noted for ascent on a wire mesh screen, open field activity, automated motor activity, avoidance conditioning, operant conditioning.; - For the low-dose group, no effects were observed on rotarod, open field activity, automated motor activity, avoidance conditioning, operant conditioning.; The following differences in neurochemical measurements in the brain between control and treated offspring were observed:; - 53% decrease in norepinephrine in the cerebellum at 12,000 mg/m^3^.^a^; - 57% decrease in met-enkephalin in the cerebrum at 12,000 mg/m^3^ and 83% decrease at 6,000 mg/m^3^.^a^; - 61% decrease in β-endorphin in the cerebellum at 12,000 mg/m^3^.^a^; - 67% decrease in serotonin in the midbrain at 6,000 mg/m^3^.^a^; - No effects were observed for other neurotransmitter levels (acetylcholine, dopamine, substance P) at both low and high doses.
Nelson et al. (1991); Adult male Sprague-Dawley rats (18/treatment) mated to untreated females; Inhalation analytical concentration: 0, 6,000, or 12,000 mg/m^3^; dynamic whole-body chamber; 7 h/d for 6 wk | Data were not presented specifically by dose nor were any tables or figures of the data provided.; Results (generally only specified as paternally treated vs. controls) in offspring indicate:; - Increase in rotarod performance (16 vs. 20 revolutions/min for the control and 12,000 mg/m^3^ animals, respectively).^a^; - Decreased time in open field (less time to reach the outer circle of the field, 210 vs. 115 sec for controls and 12,000 mg/m^3^ animals, respectively).^a^; The following differences in neurochemical measurements in the brain between control and treated offspring were observed:; - 39% decrease in norepinephrine in the cerebellum at 12,000 mg/m^3^.^a^.; - 40% decrease in met-enkephalin in the cerebrum at 12,000 mg/m^3^ and 75% decrease at 6,000 mg/m^3^.^a^; - 71% decrease in β-endorphin in the cerebellum at 12,000 mg/m^3^.^a^; - 47% decrease in serotonin in the midbrain at 6,000 mg/m^3^.^a^

w/v = weight by volume.

a Statistically significant p ≤ 0.05, as determined by the study authors.

Note: Conversions from diet concentrations to mg/kg-d were performed by the study authors.

Percentage change compared to control = [(treated value − control value) ÷ control value] × 100.

#### Mechanistic Evidence

No mechanistic evidence for neurodevelopmental effects was identified by the literature search. The available mechanistic information for tert-butanol is limited to three studies examining muscarinic acetylcholine receptor function, and what, if any, relationship these effects might have pertaining to developmental neurotoxicity effects remains unclear (Bale and Lee, 2016).

#### Integration of Neurodevelopmental Effects

Neurodevelopmental effects, including decreased brain weight, changes in brain biochemistry, and changes in behavioral performances, have been observed. Each study evaluating neurodevelopmental effects, however, had limitations in study design, reporting, or both. In addition, results were not always consistent between studies or across dose. Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify neurodevelopmental effects as a potential human health hazard of tert-butanol exposure.

### 1.2.5 Reproductive Effects

#### Synthesis of Effects Related to Reproduction

Several studies evaluated reproductive effects [a one-generation, oral reproductive study (Huntingdon Life Sciences, 2004) and subchronic effects in rats and mice following oral and inhalation exposure (NTP, 1997, 1995)] in animals exposed to tert-butanol via oral gavage, drinking water, or inhalation for ≥63 days. The studies are arranged in the evidence tables by sex, route of exposure, duration of exposure, and species. The collection of studies evaluating reproductive effects of tert-butanol is limited by the absence of two-generation reproductive oral or inhalation studies and by the lack of human studies on reproduction. The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment.

Reproductive endpoints, such as reproductive organ weights, estrous cycle length, and sperm effects were examined following either oral or inhalation exposure [Huntingdon Life Sciences (2004); NTP (1997, 1995); see Table 1-15; Figure 1-13; Figure 1-14]. In males, the only significant effect observed was a slight decrease in sperm motility for F0 males treated with 1,000 mg/kg-day tert-butanol (Huntingdon Life Sciences, 2004). No significant changes in sperm motility were reported following oral exposure in other rat studies or via inhalation exposure in mice or rats. In addition, the reduced motility in treated animals falls within the range of historical control data, and therefore, its biological significance is uncertain. In female B6C3F1 mice, estrous cycle length was increased 28% following oral exposure to 11,620 mg/kg-day (NTP, 1995). No significant changes in estrous cycle length were observed following oral exposure in rats or inhalation exposure in mice or rats. However, there was some evidence of increased numbers of animals with long, unclear, or absent cycles in tert-butanol-exposed mice (oral/inhalation) and rats (oral; see Table 1-15). It is noteworthy that these effects were limited to the highest doses tested with some doses accompanied by body-weight loss or lethality.

Table 1-15 Evidence pertaining to reproductive effects in animals following exposure to tert-butanol

Reference and study design | Results
Male reproductive effects
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; F0 males: 9 wk beginning 4 wk prior to mating; PND 21 | F0 reproductive effects; Sperm motility (only control and high-dose groups examined); 0: 94% 1,000: 91%^a^; No other significant effect on weights of male reproductive organs or sperm observed.
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^b^ mg/kg-d; 13 wk | No significant effect on weights of male reproductive organs or sperm observed.
NTP (1995); B6C3F1 mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 350, 640, 1,590, 3,940, or 8,210^b^ mg/kg-d; 13 wk | No significant effect on weights of male reproductive organs or sperm observed.; Note: NTP results unclear in regard to testis weight–Table F3 shows a significant decrease in testis weight at 8,210 mg/kg-d (0.115 to 0.096 mg) but Table H2 shows the same dose decreasing testis weight nonsignificantly from 0.115 to 0.101 mg.
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273, or 6,368 mg/m^3^), dynamic whole-body chamber; 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No significant effect on weights of male reproductive organs or sperm observed.; Evaluations were performed only for concentrations ≥542 ppm (1,643 mg/m^3^).
NTP (1997); B6C3F_1_ mouse; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273, or 6,368 mg/m^3^), dynamic whole-body chamber; 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No significant effect on weights of male reproductive organs or sperm observed.; Evaluations were performed only for concentrations ≥542 ppm (1,643 mg/m^3^).
Female reproductive effects
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; F0 females: 4 wk prior to mating through PND 21 | Pregnancy index
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; F0 females: 4 wk prior to mating through PND 21 | 91.7% | 91.7% | 100% | | 100% | 91.7%
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); F: 0, 290, 590, 850, 1,560, or 3,620^b^ mg/kg-d; 13 wk | No significant effect on female estrous cycle length (0, −2, −4, 0, 8% change relative to control).; Note: Number of animals that had >7-d cycle length, unclear cycles, or no cycles.
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); F: 0, 290, 590, 850, 1,560, or 3,620^b^ mg/kg-d; 13 wk | 0: 0 | 1,560: 2/10 | | 3,620: 4/4^c^
NTP (1995); B6C3F1 mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); F: 0, 500, 820, 1,660, 6,430, or 11,620^b^ mg/kg-d; 13 wk | ↑ length of estrous cycle; Response relative to control: 0, 5, 5, 5, 6, 28^a^%; Note: Animals with >7-d cycle length, unclear cycles, or no cycles.
NTP (1995); B6C3F1 mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); F: 0, 500, 820, 1,660, 6,430, or 11,620^b^ mg/kg-d; 13 wk | 0: 0/10 | 500: 0/9 | 820:1/10 | 1,660: 1/10 | 6,430: 1/9 | 11,620: 4/6^d^
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273, or 6,368 mg/m^3^), dynamic whole-body chamber; 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No significant effect on female estrous cycle length (0, −4, 2, 4% change relative to control) or the number of animals cycling. Evaluations were performed only for concentrations ≥542 ppm (1,643 mg/m^3^).
NTP (1997); B6C3F1 mouse; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 pm (0, 406, 824, 1,643, 3,273, or 6,368 mg/m^3^), dynamic whole-body chamber; 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No significant effect on female estrous cycle length (0, −3, −9, −5% change relative to control).; Evaluations were only performed for concentrations ≥542 ppm (1,643 mg/m^3^).; Note: Number of animals with >7-d cycle length, unclear cycles, or no cycles.
| 0:0/10 | 542: 2/10 | 1,080: 1/10 | | 2,101: 3/10

a Statistically significant p ≤ 0.05, as determined by the study authors.

b The high-dose group had an increase in mortality.

c Statistically significant p ≤ 0.01, as determined by EPA.

d Statistically significant p ≤ 0.05, as determined by EPA.

Notes: Conversions from drinking water concentrations to mg/kg-d were performed by the study authors.

Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

Percentage change compared to control = [(treated value − control value) ÷ control value] × 100.

Figure 1-13 Exposure-response array of reproductive effects following oral exposure to tert-butanol

Sources: (A) Huntingdon Life Sciences (2004); (B) NTP (1995).

Figure 1-14 Exposure-response array of reproductive effects following inhalation exposure to tert-butanol

#### Mechanistic Evidence

No mechanistic evidence for reproductive effects was identified by the literature search.

#### Integration of Reproductive Effects

Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify reproductive effects as a potential human health hazard of tert-butanol exposure. The evidence base is limited to a one-generation study (Huntingdon Life Sciences, 2004; NTP, 1995). No two-generation reproductive studies are available that evaluate oral or inhalation exposure. In males, the only observed effect was a slight decrease in sperm motility for F0 males in the highest dose group of rats treated with tert-butanol. This effect was not observed, however, in other studies with orally treated rats and mice or in rats exposed via inhalation. In females, NTP (1995) reported an increased length of the estrous cycle in the highest dose group of orally exposed mice. This effect was not observed in similarly treated rats or in mice and rats exposed via inhalation. In addition, there was limited evidence of increased numbers of animals with long, unclear, or absent cycles in exposed rats and mice. However, these effects were limited to the highest doses tested (some with accompanying body-weight loss or lethality) and were not consistent across species or route of exposure. Furthermore, no adverse effects were reported in one- and two-generation reproductive/developmental studies on ETBE (Gaoua, 2004a, b), providing additional support for the lack of evidence supporting reproductive effects as possible human hazards following tert-butanol exposure.

### 1.2.6 Other Toxicological Effects

Effects other than those related to kidney, thyroid, reproductive, developmental, and neurodevelopmental toxicity were observed in some of the available rodent studies; these include liver and urinary bladder effects. However, because of a lack of consistency in the liver effects and the minimal to mild effects with a lack of progression in urinary bladder, the available information is inadequate to draw conclusions regarding liver or urinary bladder toxicity at this time.

Additionally, central nervous system (CNS) effects similar to those caused by ethanol (animals appearing intoxicated and having withdrawal symptoms after cessation of oral or inhalation exposure) were observed. Because of study quality concerns (e.g., lack of data reporting, small number of animals per treatment group), however, adequate information to assess CNS toxicity is unavailable at this time. For more information on these other toxicological effects, see Appendix B, Section B.3.

## 1.3 INTEGRATION AND EVALUATION

### 1.3.1 Effects Other Than Cancer

Kidney effects were identified as a potential human hazard of tert-butanol exposure based on several endpoints in female rats, including suppurative inflammation, transitional epithelial hyperplasia, severity and incidence of nephropathy, and increased kidney weights. These effects are similar to the kidney effects observed with ETBE exposure (e.g., CPN and urothelial hyperplasia) and MTBE [e.g., CPN and mineralization; ATSDR (1996)].

Based on mechanistic evidence indicating that an alpha 2u-globulin-related process is operating in male rats (Hard et al., 2011; Cirvello et al., 1995; NTP, 1995; Lindamood et al., 1992), any kidney effects may be confounded by the association with alpha 2u-globulin. However, it is difficult to determine the relevant contribution of alpha 2u-globulin and chemically induced or spontaneously occurring CPN. Thus, nephropathy in male rats is not considered relevant for human hazard identification. Furthermore, mineralization in male rats was not considered clinically important to rats or relevant to human health and was not considered for dose-response analysis.

CPN played a role in the renal tubule nephropathy observed following tert-butanol exposure in female rats. Because female rats were not affected by alpha 2u-globulin nephropathy and the individual lesions associated with the spectrum of toxicities collectively described as CPN can occur in the human kidney (NIEHS, 2019), exacerbation of one or more of these lesions might reflect a type of injury relevant to the human kidney. Effects associated with such nephropathy are considered relevant for human hazard identification and suitable for derivation of reference values. Overall, the female rat kidney effects (suppurative inflammation, transitional epithelial hyperplasia, increased severity of CPN, and increased kidney weights) are considered the result of tert-butanol exposure and relevant to human hazard characterization. These effects therefore are suitable for consideration for dose-response analysis and derivation of reference values, in Section 2.

Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify developmental effects as a potential human health hazard of tert-butanol exposure. Increased fetal loss, decreased fetal body weight, and increases in skeletal variations in exposed offspring were observed following exposure to relatively high doses of tert-butanol during gestation. These effects are similar to the developmental effects observed with MTBE exposure [e.g., decreased fetal body weight and increases in skeletal variations; ATSDR (1996)]. However, dams had body-weight losses or gains (or both), decreased food consumption, and clinical signs of intoxication at the same doses of tert-butanol causing fetal effects. Therefore, determining whether tert-butanol exposure results in specific developmental toxicity or the fetal effects are due to maternal toxicity is difficult, if not impossible, from the available data. Nevertheless, selective developmental toxicity of tert-butanol at the higher doses examined cannot be ruled out.

No mechanistic evidence is available for developmental effects of tert-butanol. There is inadequate evidence of selective developmental toxicity because of the uncertainty about whether fetal effects were due to direct effects of tert-butanol or indirect effects of maternal toxicity and because of the lack of consistency across some endpoints.

Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify neurodevelopmental effects as a potential human health hazard of tert-butanol exposure. While neurodevelopmental effects have been observed, the studies had limitations in design or reporting, or both, and results were inconsistent between and across exposure routes and species. Also, the limited available mechanistic information is unclear. Therefore, neurodevelopmental effects were not considered further for dose-response analysis and derivation of reference values.

Although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify reproductive effects as a potential human health hazard of tert-butanol exposure. The only reproductive effect observed due to tert-butanol exposure was increased length of estrous cycle (NTP, 1995) in the highest dose group of orally exposed mice, and this effect was not observed in orally exposed rats or in mice and rats exposed via inhalation. Further, the evidence base was limited and contained only two oral exposure studies and one subchronic inhalation study. No mechanistic or MOA information is available for reproductive effects of tert-butanol. These effects were not considered further for dose-response analysis and the derivation of reference values.

At this time, information is inadequate to draw conclusions regarding liver or urinary bladder toxicity due to lack of consistency of effects and minimal/mild effects showing a lack of progression, respectively. No mechanistic evidence is available for these effects. The liver and urinary bladder effects were not considered further for dose-response analysis and the derivation of reference values.

### 1.3.2 Carcinogenicity

#### Summary of Evidence

In B6C3F1 mice, administration of tert-butanol in drinking water increased the incidence of thyroid follicular cell adenomas in females and adenomas or carcinomas (only one carcinoma observed) in males (NTP, 1995), as discussed in Section 1.2.2. According to EPA’s thyroid tumor guidance (U.S. EPA, 1998a), chemicals that produce thyroid tumors in rodents might pose a carcinogenic hazard to humans.

In F344/N rats, administration of tert-butanol in drinking water increased the incidence of renal tubule tumors, mostly adenomas, in males; no renal tumors in females were reported (Hard et al., 2011; NTP, 1995). As discussed in Section 1.2.1, some of these tumors might be associated with alpha 2u-globulin nephropathy, an MOA considered specific to the male rat (U.S. EPA, 1991a). Evidence in support of this hypothesized MOA includes the accumulation of hyaline droplets in renal tubule cells, the presence of alpha 2u-globulin in the hyaline droplets, and additional aspects associated with alpha 2u-globulin nephropathy, including linear papillary mineralization and foci of tubular hyperplasia. Other evidence, however, is not supportive: the accumulation of hyaline droplets was minimal, concentrations of alpha 2u-globulin were low at doses that induced tumors, and no significant necrosis or cytotoxicity was associated with compensatory regenerative proliferation or induction of granular casts observed within a time frame consistent with alpha 2u-globulin-mediated nephropathy. Renal tumors also are associated with chronic progressive nephropathy, but the data on CPN are not coherent; dose-response relationships for CPN, renal tubule hyperplasia, and renal tubule tumors differed. In addition, CPN was nearly as severe in female rats as in male rats, yet no female rats developed renal tumors. Thus, some renal tumors might be attributable to alpha 2u-globulin nephropathy augmented by CPN, and some to other, yet unspecified, processes. Taken together, and according to EPA’s guidance on renal tumors in male rats (U.S. EPA, 1991a), renal tumors induced by tert-butanol are relevant for human hazard identification.

In addition, as mentioned in Section 1.1.4, tert-butanol is a primary metabolite of MTBE and of ETBE, two compounds tested in rats and mice that could provide supplementary information on the carcinogenicity of tert-butanol. For MTBE, the most recent cancer evaluation by a national or international health agency is from IARC (1999). IARC reported that oral gavage exposure in Sprague-Dawley rats resulted in testicular tumors in males and lymphomas and leukemias (combined) in females. Inhalation exposure in male and female F344 rats resulted in renal tubule adenomas in males, and inhalation exposure in male and female CD-1 mice resulted in hepatocellular adenomas in females (IARC, 1999). For ETBE, the IRIS assessment developed concurrently with this assessment reports that inhalation exposure in male and female F344 rats resulted in hepatocellular tumors, primarily adenomas, in males. No significant tumor increases, including kidney tumors, were reported for 2-year studies by drinking water exposure in male and female F344 rats or by gavage in male and female Sprague-Dawley rats (NTP, 1997).

##### Integration of evidence

This evidence leads to consideration of two hazard descriptors under EPA Cancer Guidelines (U.S. EPA, 2005b). The descriptor likely to be carcinogenic to humans is appropriate when the evidence is “adequate to demonstrate carcinogenic potential to humans” but does not support the descriptor carcinogenic to humans. One example from the cancer guidelines is “an agent that has tested positive in animal experiments in more than one species, sex, strain, site, or exposure route, with or without evidence of carcinogenicity in humans.” tert-Butanol matches the conditions of this example, having increased tumor incidences in two species, in both sexes, and at two sites.

Alternatively, the descriptor suggestive evidence of carcinogenic potential is appropriate when the evidence raises “a concern for potential carcinogenic effects in humans” but is not sufficient for a stronger conclusion. The results for tert-butanol raise a concern for cancer but none of the effects is particularly strong. The thyroid tumors induced in male and female mice were almost entirely benign. The kidney tumors resulted, in part, from an MOA that is specific to male rats, while no kidney tumors occurred in female rats. In addition, while MTBE was also associated with male rat kidney tumorigenesis, results between tert-butanol- and ETBE-associated tumorigenesis in rats have little coherence. MTBE or ETBE effects following chronic oral exposure in mice have not been investigated, however, so no evidence exists to evaluate the coherence of the thyroid tumorigenesis observed following tert-butanol exposure in B6C3F1 mice.

These considerations, interpreted in light of the cancer guidelines, support the conclusion, suggestive evidence of carcinogenic potential for tert-butanol. Although increased tumor incidences were reported for two species, two sexes, and two sites, none of the tumor responses were strong or coherent with the results for ETBE, and this was decisive in selecting a hazard descriptor.

The descriptor suggestive evidence of carcinogenic potential applies to all routes of human exposure. Oral administration of tert-butanol to rats and mice induced tumors at sites beyond the point of initial contact, and inhalation exposure for 13 weeks resulted in absorption and distribution of tert-butanol into the systemic circulation, as discussed in Section 1.2.1. Therefore, in agreement with EPA Cancer Guidelines, this information provides sufficient basis to apply the cancer descriptor developed from oral studies to other exposure routes.

##### Biological considerations for dose-response analysis

Regarding hazards to bring forward to Section 2 for dose-response analysis, EPA’s guidance on thyroid tumors (U.S. EPA, 1998a) advise that, for thyroid tumors resulting from thyroid-pituitary disruption, dose-response analysis should use nonlinear extrapolation, in the absence of MOA information to indicate otherwise. As discussed in Section 1.2.2, increases in thyroid follicular cell hyperplasia in male and female mice provide partial support for thyroid-pituitary disruption. Other necessary data on tert-butanol, however, are either not adequate or not supportive. There is little correlation between thyroid, pituitary, and liver effects in female mice, and no data are available to evaluate the potential for antithyroid effects in male mice. Data are not adequate to conclude that thyroid hormone changes exceed the range of homeostatic regulation or to evaluate effects on extrahepatic sites involved in thyroid-pituitary disruption. Also, no data are available to evaluate reversibility of effects upon cessation of exposure. Thus, according to EPA’s thyroid tumor guidance, concluding that the thyroid tumors result from thyroid-pituitary disruption is premature, and dose-response analysis should use linear extrapolation.

As discussed in Section 1.2.2, the available data do not demonstrate that the thyroid tumors are the result of excessive toxicity in female mice rather than the carcinogenicity of tert-butanol. The final average body-weight reduction in female mice was 12% (NTP, 1995), but water consumption by exposed females was similar to controls and no overt toxicity was observed. Furthermore, female mice in the high-dose group had higher rates of survival than control animals. EPA Cancer Guidelines (U.S. EPA, 2005a) also states that when there is suggestive evidence of carcinogenicity and when the evidence includes a well-conducted study, “quantitative analysis may be useful for some purposes, for example, providing a sense of magnitude and uncertainty of potential risk, ranking potential hazards, or setting research priorities.” Given that the data are well suited to dose-response analysis, coming from an NTP study that tested multiple dose levels, and because quantitative analysis may be useful in providing a sense of magnitude and uncertainty of potential risks from tert-butanol exposure, including worker or consumer exposures, an analysis of thyroid tumors is presented in Section 2.

EPA’s guidance on renal tumors in male rats (U.S. EPA, 1991a) advises that, unless the relative contribution of alpha 2u-globulin nephropathy and other process can be determined, dose-response analysis should not be performed. As discussed in Section 1.2.1, the available data do not allow such determination, and so an analysis of kidney tumors does not appear in Section 2.

### 1.3.3 Susceptible Populations and Lifestages for Cancer and Noncancer Outcomes

No chemical-specific data that would allow for the identification of populations with increased susceptibility to tert-butanol exposure are available. In vitro studies have implicated the liver microsomal mixed function oxidase system, namely CYP450 (Cederbaum et al., 1983; Cederbaum and Cohen, 1980), as playing a role in the metabolism of tert-butanol. One study evaluated liver enzyme expression and found a dose-responsive induction of CYP2B10 following 14 days of tert-butanol exposure in female mice, with much smaller increases in the expression of CYP2B9 and the thyroid hormone-metabolizing enzyme SULT1A1 (Blanck et al., 2010). No studies, however, have identified the specific CYPs responsible for the biotransformation of tert-butanol. Pharmacokinetic differences among the fetus, newborns, children, and the aged might alter responses to chemicals compared with adults, resulting in differences in health effects. In the presence of environmental chemicals, metabolic homeostasis is maintained by the liver’s ability to detoxify and eliminate xenobiotics. This process is accomplished, in part, by the expression of xenobiotic metabolizing enzymes and transporters (XMETs), which metabolize and transport xenobiotics and determine whether exposure will result in altered responses. XMETs, including various CYPs, have been found to be underexpressed in the mouse fetus and neonate (Lee et al., 2011) and decreased in older mice (Lee et al., 2011) and rats (Lee et al., 2008). Decreased ability to detoxify and transport tert-butanol out of the body could result in increased susceptibility to tert-butanol in the young and old.

In regard to cancer, although children are more sensitive than adults to thyroid carcinogenesis resulting from ionizing radiation, relative differences in lifestage sensitivity to chemically induced thyroid carcinogenesis are unknown (U.S. EPA, 1998a). In addition, the data on tert-butanol mutagenicity are inconclusive.

Collectively, evidence on tert-butanol is minimal for identifying susceptible populations or lifestages.

9 If the chemical meets the criteria for question one, then a second question is asked: Are the renal effects in male rats exposed to this chemical due solely to the alpha 2u-globulin process?

10 When the alpha 2u-globulin process is occurring, U.S. EPA (1991a) states that one of the following conclusions will be made: (a) if renal tumors in male rats are attributable solely to the alpha 2u-globulin process, such tumors will not be used for human cancer hazard identification or for dose-response extrapolations; (b) if renal tumors in male rats are not linked to the alpha 2u-globulin process, such tumors are an appropriate endpoint for human hazard identification and are considered, along with other appropriate endpoints, for quantitative risk estimation; or (c) if some renal tumors in male rats are attributable to the alpha 2u-globulin process and some are attributable to other carcinogenic processes, such tumors remain relevant for purposes of hazard identification, but a dose-response estimate based on such tumors in male rats should not be performed unless enough information is available to determine the relative contribution of each process to the overall renal tumor response.