# REFERENCES

Acharya, S; Mehta, K; Rodrigues, S; Pereira, I; Krishnan, S; Rao, CV. (1995). Administration of subtoxic doses of t-butyl alcohol and trichloroacetic acid to male Wistar rats to study the interactive toxicity. Toxicology Letters 80: 97–104. 10.1016/0378-4274(95)03340-Q 7482597
Acharva, S; Mehta, K; Rodriguez, S; Pereira, J; Krishnan, S; Rao, CV. (1997). A histopathological study of liver and kidney in male Wistar rats treated with subtoxic doses of t-butyl alcohol and trichloroacetic acid. Experimental and Toxicologic Pathology 49: 369–373. 10.1016/S0940-2993(97)80119-4 9455684
Amberg, A; Rosner, E; Dekant, W. (1999). Biotransformation and kinetics of excretion of methyltert-butanol ether in rats and humans. Toxicological Sciences 51: 1–8.10496672
Amberg, A; Rosner, E; Dekant, W. (2000). Biotransformation and kinetics of excretion of ethyl tert-butanol ether in rats and humans. Toxicological Sciences 53: 194–201. 10.1093/toxsci/53.2.194 10696767
Andersen, ME. (1991). Physiological modelling of organic compounds. Annals of Occupational Hygiene 35: 309–321. 10.1093/annhyg/35.3.309 1888102
ARCO (ARCO Chemical Company). (1983). Toxicologist’s report on metabolism and pharmacokinetics of radiolabeled TBA 534 tertiary butyl alcohol with cover letter dated 03/24/1994. (8EHQ86940000263). Newton Square, PA.
Arslanian, MJ; Pascoe, E; Reinhold, JG. (1971). Rat liver alcohol dehydrogenase. Purification and properties. Biochemical Journal 125: 1039–1047. 10.1042/bj1251039 4335536
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Toxicological profile for methyl-tert-butanol ether [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp91.pdf
Bailer, AJ; Portier, CJ. (1988). Effects of treatment-induced mortality and tumor-induced mortality on tests for carcinogenicity in small samples. Biometrics 44: 417–431. 10.2307/2531856 3390507
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicologic Pathology 32: 448–466. 10.1080/01926230490465874 15204968
Baker, RC; Sorensen, SM; Deitrich, RA. (1982). The in vivo metabolism of tertiary butanol by adult rats. Alcoholism: Clinical and Experimental Research 6: 247–251. 10.1111/j.1530-0277.1982.tb04970.x 7048978
Bernauer, U; Amberg, A; Scheutzow, D; Dekant, W. (1998). Biotransformation of 12C- and 2-13C-labeled methyl tert-butanol ether, ethyl tert-butanol ether, and tert-butanol alcohol in rats: Identification of metabolites in urine by 13C nuclear magnetic resonance and gas chromatography/mass spectrometry. Chemical Research in Toxicology 11: 651–658. 10.1021/tx970215v 9625733
Blancato, JN; Evans, MV; Power, FW; Caldwell, JC. (2007). Development and use of PBPK modeling and the impact of metabolism on variability in dose metrics for the risk assessment of methyl tertiary butyl ether (MTBE). Journal of Environmental Protection Science 1: 29–51.
Bond, JA; Medinsky, MA; Wolf, DC; Cattley, R; Farris, G; Wong, B, (1996). Ethyl tertiary butyl ether (ETBE): Ninety-day vapor inhalation toxicity study in CD-1 mice [TSCA Submission] (pp. 1–69). (Laboratory Project ID 95030). Research Triangle Park, NC: Chemical Industry Institute of Toxicology under contract to ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0573631
Borghoff, SJ; Asgharian, B. (1996). Ethyl tertiary-butyl ether (ETBE): Pharmacokinetic study in male and female CD-1 mice after single inhalation exposure and male and female F-344 rats after single and repeated inhalation exposure. (CUT Protocol 95026). La Palma, CA: ARCO Chemical Company.
Borghoff, SJ; Murphy, JE; Medinsky, MA. (1996). Development of a physiologically based pharmacokinetic model for methyl tertiary-butyl ether and tertiary-butanol in male Fischer-344 rats. Toxicological Sciences 30: 264–275. 10.1006/faat.1996.0064
Borghoff, SJ; Parkinson, H; Leavens, TL. (2010). Physiologically based pharmacokinetic rat model for methyl tertiary-butyl ether; comparison of selected dose metrics following various MTBE exposure scenarios used for toxicity and carcinogenicity evaluation. Toxicology 275: 79–91. 10.1016/j.tox.2010.06.003 20561556
Borghoff, SJ; Prescott, JS; Janszen, DB; Wong, BA; Fveritt, JI. (2001). alpha2u-Globulin nephropathy, renal cell proliferation, and dosimetry of inhaled tert-butanol alcohol in male and female F-344 rats. Toxicological Sciences 61: 176–186. 10.1093/toxsci/61.1.176 11294988
Borghoff, SJ; Ring, C; Banton, MI; Leavens, TL. (2016). Physiologically based pharmacokinetic model for ethyl tertiary-butyl ether and tertiary-butyl alcohol in rats: Contribution of binding to α2u-globulin in male rats and high-exposure nonlinear kinetics to toxicity and cancer outcomes. Journal of Applied Toxicology 37: 621–640. 10.1002/jat.3412 27885692
Brown, RP; Delp, MD; Lindstedt, SL; Rhomberg, LR; Beliles, RP. (1997). Physiological parameter values for physiologically based pharmacokinetic models. Toxicology and Industrial Health 13: 407–484. 10.1177/074823379701300401 9249929
Capen, CC; Dybing, E; Rice, JM; Wilbourn, JD. (1999). Species differences in thyroid, kidney and urinary bladder carcinogenesis. In CC Capen; E Dybing; JM Rice; JD Wilbourn (Eds.), (pp. 1–225). Lyon, France: International Agency for Research on Cancer.
Carruthers, L; Reeves, K; Paul, M; Searle, A; Templeton, W; Paine, AJ. (1987). The role of “alpha”2u globulin synthesis in the production of renal hyaline droplets by iso-octane. Biochemical Pharmacology 36: 2577–2580.2440446
Cederbaum, AI: Cohen, G. (1980). Oxidative demethylation of t-butyl alcohol by rat liver microsomes. Biochemical and Biophysical Research Communications 97: 730–736. 10.1016/0006-291X(80)90325-3 7470124
Cederbaum, AI; Qureshi, A; Cohen, G. (1983). Production of formaldehyde and acetone by hydroxyl-radical generating systems during the metabolism of tertiary butyl alcohol. Biochemical Pharmacology 32: 3517–3524. 10.1016/0006-2952(83)90297-6 6316986
Charbonneau, M; Lock, EA; Strasser, J; Cox, MG; Turner, MJ; Bus, JS. (1987). 2,2,4-trimethylpentane-induced nephrotoxicity: I metabolic disposition of TMP in male and female Fischer 344 rats. Toxicology and Applied Pharmacology 91:171–181.2445050
Dickey, FH; Cleland, GH; Lotz, C. (1949). The role of organic peroxides in the induction of mutations. Proceedings of the National Academy of Sciences 35: 581–586.
Edwards, EK. Jr.; Edwards, EK. (1982). Allergic reaction to tertiary butyl alcohol in a sunscreen. Cutis 29: 476–478.7094633
Faulkner, TP; Wiechart, JD; Hartman, DM; Hussain, AS. (1989). The effects of prenatal tertiary butanol administration in CBA/J and C57BL/6J mice. Life Sciences 45: 1989–1995.2601562
FDA (U.S. Food and Drug Administration). (2015a). Indirect food additives: Adjuvants, production aids, and sanitizers. Surface lubricants used in the manufacture of metallic articles. 21 CFR 178.3910 (pp. 1–7). http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?fr=178.3910
FDA (U.S. Food and Drug Administration). (2015b). Indirect food additives: Paper and paperboard components. Defoaming agents used in coatings. 21 CFR 176.200 (pp. 1–4). http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?fr=l76.200
Frazier, KS; Seelv, JC; Hard, GC; Betton, G; Burnett, R; Nakatsuii, S. (2012). Proliferative and nonproliferative lesions of the rat and mouse urinary system. Toxicologic Pathology 40: 14S–86S. 10.1177/0192623312438736 22637735
Fujii, S; Yabe, K; Furukawa, M; Matsuura, M; Aoyama, H. (2010). A one-generation reproductive toxicity study of ethyl tertiary butyl ether in rats. Reproductive Toxicology 30: 414–421. 10.1016/j.reprotox.2010.04.013 20438832
Galloway, SM; Deasy, DA; Bean, CL; Kraynak, AR; Armstrong, MJ; Bradley, MO. (1987). Effects of high osmotic strength on chromosome aberrations, sister-chromatid exchanges and DNA strand breaks, and the relation to toxicity. Mutation Research 189: 15–25. 10.1016/0165-1218(87)90029-2 3627148
Gaoua, W. (2004). Ethyl tertiary butyl ether (ETBE): Two-generation study (reproduction and fertility effects) by the oral route (gavage) in rats. (CIT Study No. 24859 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Grant, KA; Samson, HH. (1981). Development of physical dependence on t-butanol in rats: An examination using schedule-induced drinking. Pharmacology, Biochemistry and Behavior 14: 633–637. 10.1016/0091-3057(81)90124-6 7195578
Hard, GC; Banton, MI; Bretzlaff, RS; Dekant, W; Fowles, JR; Mallett, AK, (2013). Consideration of rat chronic progressive nephropathy in regulatory evaluations for carcinogenicity. Toxicological Sciences 132: 268–275. 10.1093/toxsci/kfs305 23104430
Hard, GC; Bruner, RH; Cohen, SM; Pletcher, JM; Regan, KS. (2011). Renal histopathology in toxicity and carcinogenicity studies with tert-butanol alcohol administered in drinking water to F344 rats: A pathology working group review and re-evaluation. Regulatory Toxicology and Pharmacology 59: 430–436. 10.1016/j.yrtph.2011.01.007 21296119
Hard, GC; Johnson, KJ; Cohen, SM. (2009). A comparison of rat chronic progressive nephropathy with human renal disease-implications for human risk assessment [Review]. Critical Reviews in Toxicology 39: 332–346. 10.1080/10408440802368642 19514917
Hard, GC; Khan, KN. (2004). Invited review: A contemporary overview of chronic progressive nephropathy in the laboratory rat, and its significance for human risk assessment [Review]. Toxicologic Pathology 32: 171–180. 10.1080/01926230490422574 15200155
HSDB (Hazardous Substances Data Bank). (2007). t-Butyl alcohol [Database]. Bethesda, MD; National Library of Medicine. Retrieved from https://pubchem.ncbi.nlm.nih.gov/compound/6386
Huntingdon Life Sciences. (2004). Reproductive and developmental toxicity screening test in rats by oral gavage. (Study No. 03-4254). East Millstone, NJ; Lyondell Chemical Company.
Jiménez, J; Longo, E; Benítez, T. (1988). Induction of petite yeast mutants by membrane-active agents. Applied and Environmental Microbiology 54: 3126–3132.3066293
JPEC (Japan Petroleum Energy Center). (2008a). A 90-day repeated dose toxicity study of ETBE by whole-body inhalation exposure in rats. (Study Number: B061829). Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008b). A 180-Day repeated dose oral toxicity study of ETBE in rats. (Study Number: D19-0002). Japan: Hita Laboratory, Chemicals Evaluation and Research Institute (CERI).
JPEC (Japan Petroleum Energy Center). (2008c). A one-generation reproduction toxicity study of ETBE in rats. (Study Number: SR07060). Safety Research Institute for Chemical Compounds.
JPEC (Japan Petroleum Energy Center). (2008d). Pharmacokinetic study in rats treated with [14c] ETBE repeatedly for 14 days. (P070497). Japan: Kumamoto Laboratory, Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2010a). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Drinking water study). (Study No: 0691). Japan Industrial Safety and Health Association, Japan Bioassay Research Center.
JPEC (Japan Petroleum Energy Center). (2010b). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Inhalation study). (Study No: 0686). Japan: Japan Industrial Safety and Health Association.
Kaneko, T; Wang, PY; Sato, A. (2000). Partition coefficients for gasoline additives and their metabolites. Journal of Occupational Health 42: 86–87. 10.1539/joh.42.86
Kim, D; Andersen, ME; Pleil, JD; Nylander-French, LA; Prah, JD. (2007). Refined PBPK model of aggregate exposure to methyl tertiary-butyl ether. Toxicology Letters 169: 222–235. 10.1016/j.toxlet.2007.01.008 17336003
Kirkland, D; Aardema, M; Henderson, L; Müller, L. (2005). Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens: I. Sensitivity, specificity and relative predictivity. Mutation Research 584:1–256. 10.1016/j.mrgentox.2005.02.004 15979392
Leavens, TL; Borghoff, SJ. (2009). Physiologically based pharmacokinetic model of methyl tertiary butyl ether and tertiary butyl alcohol dosimetry in male rats based on binding to alpha2uglobulin. Toxicological Sciences 109: 321–335. 10.1093/toxsci/kfp049 19270017
Lusco, MA; Fogo, AB; Najafian, B; Alpers, CE. (2016). AJKD Atlas of Renal Pathology: Tubular Atrophy. American Journal of Kidney Diseases 67: e33–e34. 10.1053/j.ajkd.2016.04.007 27211375
Mansouri, K; Grulke, CM; Richard, AM; Judson, RS; Williams, AJ. (2016). An automated curation procedure for addressing chemical errors and inconsistencies in public datasets used in QSAR modelling. SAR and QSAR in Environmental Research 27: 911–937. 10.1080/1062936X.2016.1253611 27885861
McComb, JA; Goldstein, DR. (1979a). Additive physical dependence: Evidence for a common mechanism in alcohol dependence. Journal of Pharmacology and Experimental Therapeutics 210: 87–90.571913
McComb, JA; Goldstein, DB. (1979b). Quantitative comparison of physical dependence on tertiary butanol and ethanol in mice: Correlation with lipid solubility. Journal of Pharmacology and Experimental Therapeutics 208: 113–117.569697
Mcgregor, DB; Brown, A; Cattanach, P; Edwards, I; Mcbride, D; Caspary, WJ. (1988). Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environmental and Molecular Mutagenesis 11: 91–118. 10.1002/em.2850110110 3338442
McGregor, DB; Cruzan, G; Callander, RD; May, K; Banton, M. (2005). The mutagenicity testing of tertiary-butyl alcohol, tertiary-butyl acetate and methyl tertiary-butyl ether in Salmonella typhimurium. Mutation Research 565: 181–189. 10.1016/j.mrgentox.2004.10.002 15661616
Medinsky, MA; Kimbell, JS; Morris, JB; Gerde, P; Overton, JH. (1993). Advances in biologically based models for respiratory tract uptake of inhaled volatiles [Review]. Toxicological Sciences 20: 265–272.
Medinsky, MA; Wolf, DC; Cattley, RC; Wong, B; Janszen, DB; Farris, GM, (1999). Effects of a thirteen-week inhalation exposure to ethyl tertiary butyl ether on Fischer-344 rats and CD-1 mice. Toxicological Sciences 51: 108–118. 10.1093/toxsci/51.1.108 10496682
Miyata, K; Koga, T; Aso, S; Hoshuyama, S; Ajimi, S; Furukawa, K. (2013). A sub chronic (180-day) oral toxicity study of ethyl tertiary-butyl ether, a bioethanol, in rats. Drug and Chemical Toxicology. 10.3109/01480545.2013.851690
NIEHS (National Institute of Environmental Health Sciences). (2019). NTP pathology consult for ETBE and tBA. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
Nihlén, A; Johanson, G. (1999). Physiologically based toxicokinetic modeling of inhaled ethyl tertiary-butyl ether in humans. Toxicological Sciences 51: 184–194. 10.1093/toxsci/51.2.184 10543020
Nihlén, A; Löf. A; Johanson, G. (1995). Liquid/air partition coefficients of methyl and ethyl t-butyl ethers, t-amyl methyl ether, and t-butyl alcohol. Journal of Exposure Analysis and Environmental Epidemiology 5: 573–582.8938250
Nihlén, A; Löf, A; Johanson, G. (1998a). Controlled ethyl tert-butanol ether (ETBE) exposure of male volunteers: I Toxicokenetics. Toxicological Sciences 46:1–10. 10.1006/toxs.1998.2516 9928663
Nihlén, A; Löf, A; Johanson, G. (1998b). Experimental exposure to methyl tertiary-butyl ether: I Toxicokinetics in humans. Toxicology and Applied Pharmacology 148: 274–280. 10.1006/taap.1997.8333 9473535
NIOSH (National Institute for Occupational Safety and Health). (2007). NIOSH pocket guide to chemical hazards. (DHHS Publication No. (NIOSH) 2005–149; CBRNIAC-CB-112149). Cincinnati, OH. http://www.cdc.gov/niosh/docs/2005-149/
NSF International. (2003). t-Butanol: Oral Risk Assessment Document (CAS 75-65-0) (pp. 81). Ann Arbor, MI.
NTP (National Toxicology Program). (1995). Toxicology and carcinogenesis studies of t-butyl alcohol (CAS no 75-65-0) inF344/N rats and B6C3F1 mice (Drinking water studies). (NTPTR436). Research Triangle Park, NC: U.S. Department of Health, Public Health Service, National Institutes of Health, https://ntp.niehs.nih.gov/ntp/htdocs/lt_rptsZtr436.pdf
NTP (National Toxicology Program). (1997). NTP technical report on toxicity studies of t-butyl alcohol (CAS no 75-65-0) administered by inhalation to F344/N rats and B6C3F1 mice. (NIH Pub 97-3942). Research Triangle Park, NC; U.S. Department of Health, Public Health Service, National Institutes of Health, http://ntp.niehs.nih.gov/ntp/htdocs/STrpts/tox053.pdf
Olson, MJ; Garg, BD; Murty, CV; Roy, AK. (1987). Accumulation of alpha 2u-globulin in the renal proximal tubules of male rats exposed to unleaded gasoline. Toxicology and Applied Pharmacology 90: 43–51. 10.1016/0041-008X(87)90304-8 2442852
OSHA (Occupational Safety & Health Administration). (2006). Table Z-l: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. (OSHA standard 1910.1000, 29 CFR). Washington, DC: U.S. Department of Labor. http://www.osha.gov/pls/oshaweb/owadisp.showdocument?ptable=STANDARDS&pid=9992
Peter, CP; Burek, JD; Zwieten, MJV. (1986). Spontaneous nephropathies in rats. Toxicologic Pathology 14: 91–100. 10.1177/019262338601400111 3715332
Poet, TS; Valentine, JL; Borghoff, SJ. (1997). Pharmacokinetics of tertiary butyl alcohol in male and female Fischer 344 rats. Toxicology Letters 92: 179–186. 10.1016/S0378-4274(97)00056-8 9334828
Rao, HV; Ginsberg, GL. (1997). A physiologically-based pharmacokinetic model assessment of methyl t-butyl ether in groundwater for a bathing and showering determination. Risk Analysis 17: 583–598. 10.1111/j.1539-6924.1997.tb00899.x 9404048
Saito, A; Sasaki, T; Kasai, T; Katagiri, T; Nishizawa, T; Noguchi, T. (2013). Hepatotumorigenicity of ethyl tertiary-butyl ether with 2-year inhalation exposure in F344 rats. Archives of Toxicology 87: 905–914. 10.1007/s00204-012-0997-x 23389738
Salazar, KD; Brinkerhoff, CJ; Lee, JS; Chiu, WA. (2015). Development and application of a rat PBPK model to elucidate kidney and liver effects induced by ETBE and tert-butanol. Toxicology and Applied Pharmacology 288: 439–452. 10.1016/j.taap.2015.08.015 26341290
Satirapoj, B; Nast, CC; Adler, SG. (2012). Novel insights into the relationship between glomerular pathology and progressive kidney disease [Review]. Advances in Chronic Kidney Disease 19: 93–100. 10.1053/j.ackd.2011.12.001 22449346
Sgambato, A; Iavicoli, I; De Paola, B; Bianchino, G; Boninsegna, A; Bergamaschi, A. (2009). Differential toxic effects of methyl tertiary butyl ether and tert-butanol on rat fibroblasts in vitro. Toxicology and Industrial Health 25: 141–151. 10.1177/0748233709104867 19458137
Snell, D; Harris, RA. (1980). Impairment of avoidance behavior following short-term ingestion of ethanol, tertiary-butanol, or pentobarbital in mice. Psychopharmacologia 69: 53–57. 10.1007/BF00426521
Spiteri, NJ. (1982). Circadian patterning of feeding, drinking and activity during diurnal food access in rats. Physiology & Behavior 28: 139–147. 10.1016/0031-9384(82)90115-9 7200613
Stonard, MD; Phillips, PGN; Foster, JR; Simpson, MG; Lock, FA. (1986). alpha2u-Globulin: Measurement in rat kidney and relationship to hyaline droplets. Clinica Chimica Acta 160: 197–203. 10.1016/0009-8981(86)90142-7">10.1016/0009-8981(86)90142-7
Suzuki, M; Yamazaki, K; Kano, H; Aiso, S; Nagano, K; Fukushima, S. (2012). No carcinogenicity of ethyl tertiary-butyl ether by 2-year oral administration in rats. Journal of Toxicological Sciences 37: 1239–1246.23208438
Tang, GH; Wang, J; Zhuang, Z. (1997). [Cytotoxicity and genotoxicity of methyl tert-butanol ether and its metabolite to human leukemia cells]. Zhonghua Yufang Yixue Zazhi 31: 334–337.9863065
Thurman, RG; Winn, K; Urquhart, B. (1980). Rat brain cyclic AMP levels and withdrawal behavior following treatment with t-butanol. Advances in Experimental Medicine and Biology 126: 271–281. 6250328
U.S EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC; U.S. Environmental Protection Agency, Science Policy Council, https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015
U.S. EPA (U.S. Environmental Protection Agency). (1991a). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat (pp. 1–136). (EPA/625/3-91/019F). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchOuerv=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (1991b). Guidelines for developmental toxicity risk assessment (pp. 1–71). (EPA/600/FR-91/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplav.cfm?deid=23162
U.S, EPA. (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report] (pp. 1–409). (EPA/600/8-90/066F). Research Triangle Park, NC; U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, https://cfpub.epa.gov/ncea/risk/recordisplav.cfm?deid=71993&CFID=51174829&CFT0KEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (1998). Assessment of thyroid follicular cell tumors [EPA Report] (pp. 1–51). (EPA/630/R-97/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-ll/documents/thvroid.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2000). Benchmark dose technical guidance document [external review draft] [EPA Report] (pp. 1–96). (EPA/630/R-00/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, https://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=4727
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for Carcinogen Risk Assessment [EPA Report]. (EPA/630/P-03/00IB). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2013-09/documents/cancerguidelinesfinal3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose (pp. 1–50). (EPA/100/R-11/0001). Washington, DC; U.S. Environmental Protection Agency, Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2016). Model files for tert-butanol and ETBE.
U.S. EPA (U.S. Environmental Protection Agency). (2017). PK/PBPK model evaluation for the IRIS assessments of ethyl tertiary butyl ether (CASRN 637-92-3) and tert-butanol alcohol (CAS No. 75-65-0) (Draft) [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Pharmacokinetics Working Group.
Videla, LA; Fernández, V; de Marinis, A; Fernández, N; Valenzuela, A. (1982). Liver lipoperoxidative pressure and glutathione status following acetaldehyde and aliphatic alcohols pretreatments in the rat. Biochemical and Biophysical Research Communications 104: 965–970. 10.1016/0006-291X(82)91343-2 7073737
Williams-Hill, D; Spears, CP; Prakash, S; Olah, GA; Shamma, T; Moin, T. (1999). Mutagenicity studies of methyl-tert-butanolether using the Ames tester strain TA102. Mutation Research 446: 15–21. 10.1016/s1383-5718(99)00137-0 10613182
Williams, AJ; Grulke, CM; Edwards. J; McFachran, AD; Mansouri, K; Baker, NC. (2017). The CompTox Chemistry Dashboard: A community data resource for environmental chemistry. Journal of Cheminformatics 9:61. 10.1186/s13321-017-0247-6 29185060
Williams, TM; Borghoff, SJ. (2001). Characterization of tert-butanol alcohol binding to “alpha”2u-globulin in F-344 rats. Toxicological Sciences 62: 228–235. 10.1093/toxsci/62.2.228 11452135
Wood, J; Laverty, R. (1979). Physical dependence following prolonged ethanol or t-butanol administration to rats. Pharmacology, Biochemistry and Behavior 10: 113–119. 10.1016/0091-3057(79)90176-X 571606
Yuan, Y; Wang, HF; Sun, HF; Du, HF; Xu, LH; Liu, YF. (2007). Adduction of DNA with MTBE and TBA in mice studied by accelerator mass spectrometry. Environmental Toxicology 22: 630–635. 10.1002/tox.20295 18000852
Zang, Q; Mansouri, K; Williams, AJ; Judson, RS; Allen, DG; Casev, WM. (2017). In silico prediction of physicochemical properties of environmental chemicals using molecular fingerprints and machine learning. Journal of Chemical Information and Modeling 57: 36–49. 10.1021/acs.jcim.6b00625 28006899
Zeiger, E; Anderson, B; Haworth, S; Lawlor, T; Mortelmans, K; Speck, W. (1987). Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environmental Mutagenesis 9: 1–109. 10.1002/em.2860090602
Zoia, C; Abbate, M; Remuzzi, G. (2015). Progression of renal injury toward interstitial inflammation and glomerular sclerosis is dependent on abnormal protein filtration [Review]. Nephrology, Dialysis, Transplantation 30: 706–712. 10.1093/ndt/gfu261