# APPENDIX E SUMMARY OF SCIENCE ADVISORY BOARD (SAB) PEER-REVIEW COMMENTS AND EPA’S DISPOSITION

The Toxicological Review of tert-butyl alcohol (tert-butanol; tBA), dated June 2017, underwent a formal external peer review in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S EPA, 2015). This peer review was conducted by the Chemical Assessment Advisory Committee (CAAC) Augmented for Review of the Draft IRIS tert-butanol Assessment (SAB-CAAC tert-butanol panel) of EPA’s Science Advisory Board (SAB). An external peer review workshop was held on August 15-17, 2017. Public teleconferences of the SAB-CAAC tert-butanol panel were held on July 11, 2017, March 22, 2018, March 27, 2018, and June 6, 2018. The Chartered SAB held a public meeting on September 26, 2018 to conduct a quality review of the draft SAB-CAAC peer review report.^1^ The final report of the SAB was released on February 27, 2019.

The SAB-CAAC was tasked with providing feedback in response to charge questions that addressed scientific issues related to the hazard identification and dose-response assessment of tert-butanol. Key recommendations of the SAB^2^ and EPA’s responses to these recommendations, organized by charge question, follow. Editorial changes and factual corrections offered by SAB were incorporated in the document as appropriate and are not discussed further.

## 1 Literature Search/Study Selection and Evaluation - Systematic Review Methods

### Charge Question 1 Please comment on the strategy for literature searches, criteria for study inclusion or exclusion, and evaluations of study methods and quality discussed in the Literature Search Strategy/Study Selection and Evaluation section. Were the strategies clearly described and objectively applied?

[underlined: Key Recommendation:] The SAB recommended EPA should provide clarification on the rationales for several decisions that impacted how the literature search was conducted. This includes (a) the rationale for the selection of some synonyms of tert-butanol as key search words and not others; (b) the rationale for imposing limitations on sources in the first stage of the scientific literature search (i.e., PubMed, Web of Science); and (c) the rationale for limiting the search for additional citations to only some of the publications available in peer-reviewed literature and secondary sources, but not others.

[underlined: Response]: The literature search was developed and executed in consultation with information specialists and librarians through EPA’s Health and Environmental Research Online (HERO) database. This includes developing, testing, and implementing a comprehensive literature search strategy in an iterative and collaborative manner, (a) The most common synonyms and trade names were used as the keywords in the literature search. This included the preferred IUPAC name of 2-Methylpropan-2-ol. Clarification has been added in the Literature Search Strategy/Study Selection and Evaluation Section, (b) PubMed, Web of Science, and Toxline are the core sources that IRIS uses for published studies. Prior experience has also demonstrated that searching of PubMed, Web of Science and Toxline provides sufficient coverage for literature pertinent to human health assessments. TSCATS2 database was included to capture submissions of health and safety data submitted to the EPA either as required or voluntarily under certain sections of TSCA. Based on the attributes of the chemical, along with input from HERO, EPA did not include supplemental databases (e.g., databases for pesticides, U.S. Department of Agriculture (USDA)-related compounds or inhalation values). Clarification has been added in the Literature Search Strategy/Study Selection and Evaluation Section, (c) To ensure no key studies were missed, a manual search of citations was performed on published reviews and studies identified from public comments, as well as reviews previously conducted by other international and federal health agencies. Table LS-2 lists the approach used and the sources used in the manual searching of citations.

[underlined: Key Recommendation]: The SAB recommended EPA should provide a rationale for the exclusion of studies of dermal contact as a relevant route of exposure in light of the occurrence of tert-butanol in many consumer products such as perfumes and cosmetics.

[underlined: Response]: Studies evaluating dermal exposure were not excluded (see Table LS-3 on inclusion-exclusion criteria). Several studies were identified that examined acute dermal exposures; however, as stated in the Literature Search Strategy/Study Selection and Evaluation Section, studies investigating the effects of acute dermal chemical exposures are generally less pertinent for characterizing health hazards associated with chronic exposure, and therefore were not considered as primary evidence. These studies were considered as sources of supporting health effects data (see Figure LS-1).

[underlined: Key Recommendation]: The SAB recommended EPA should provide a justification for the complete exclusion of studies with non-mammalian species, which affects the completeness of the hazard identification.

[underlined: Response]: As described in Table LS-3, the populations of interest are humans and animals. Non-mammalian species were not included because studies in mammalian model systems are available. However, these studies were considered supplemental and retained as secondary literature and sources of contextual information as shown in Figure LS-1.

[underlined: Key Recommendation]: The SAB recommended EPA should provide more transparent documentation of the process of application of inclusion and exclusion criteria and the quality evaluation of studies, in order to support decision making by the EPA. This could be done through the HERO database.

[underlined: Response]: This assessment was conducted prior to the implementation of systematic review tools in the IRIS program, like HAWC, that could be used to document the systematic review process. Database evaluation is described in the Literature Search Strategy/Study Selection and Evaluation Section. As stated in the section, information on study evaluation is reported in evidence tables and documented in the synthesis of evidence. Study strengths and limitations are also included in the text, where relevant.

## 2 Hazard Identification-Chemical Properties and Toxicokinetics

### Charge Question 2a Chemical Properties- Is the information on chemical properties accurate?

[underlined: Key Recommendations]: The SAB recommended EPA make improvements to the chemical properties table by focusing on increasing confidence and transparency in the values presented. The SAB also recommended the use of a template focusing on the chemical properties most relevant to the chemical and the assessment. Several recommendations focused on a preference for the citation of chemical properties from primary sources, for vetting the data in cases in which more than one value is published, and for presenting rationales for the selected values.

[underlined: Response]: In response to SAB comments, EPA has revised the tert-butanol chemical properties table (Table 1-1) to present average experimental and predicted chemical properties from high quality databases as curated by EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard). EPA’s CompTox Chemicals Dashboard aggregates and presents both experimental and predicted chemical property data, with links to the source and/or model data. The experimental data are sourced from publicly available databases as well PHYSPROP downloadable files (see Mansouri et al. (2016)). Predicted chemical property data are curated from EPISuite, OPERA models (see Mansouri et al. (2016)). NICEATM models (see Zang et al. (2017)). Toxicity Estimation Software Tool (TEST) Models, and the Open PH ACTS project (as predicted by ACD/LabsEXIT). A key benefit of this aggregation of chemical properties over reporting an individual measurement is a more robust point estimate than is possible from the measure derived from any individual study, with each study reporting measurements that are expected to have some degree of error. For more information on EPA’s CompTox Chemicals Dashboard see Williams et al. (2017).

### Charge Question 2b Toxicokinetic modeling- Section B.1.5 of Appendix B in the Supplemental Information describes the application and modification of a physiologically-based toxicokinetic model of tert-butanol in rats (Borghoff et al., 2016). Is use of the model appropriate and clearly described, including assumptions and uncertainties? Are there additional peer-reviewed studies that should be considered for modeling?

[underlined: Key Recommendations:] The SAB recommended the model code should be revised to describe metabolism as a function of the free liver concentration, CVL, and metabolic parameters (e.g., Km or first order rate constants) should be re-estimated. Metabolism based upon total liver concentration, CL, is not scientifically correct.

[underlined: Response]: Model code has been revised to describe metabolism as a function of the free liver concentration and metabolic parameters have been re-estimated. The new final code is available in HERO (https://hero.epa.gov/hero/index.cfm/proiect/page/proiectid/1543/usage id/2896).

[underlined: Key Recommendations]: The SAB recommended evaluation of tert-butanol dose metrics for kidney toxicity should be compared for ETBE and tert-butanol exposures (similar to Figure 6 in Salazar et al. (2015).

[underlined: Response]: Change in absolute kidney weight in female rats as a function of estimated tert-butanol blood concentration and tert-butanol rate of metabolism for both ETBE and tert-butanol exposures has been added to Appendix B of the Supplemental Information (see Figure B-3).

[underlined: Key Recommendations]: The SAB recommended the overall presentation of the PBPK modeling should be cohesive, clear, and transparent, and should provide essential information, assumptions, results and conclusions. The text in Section 1.1.3 of the draft tert-butanol assessment and text in Appendix should be reworded. The SAB suggests that the material in U.S. EPA (2017) be included in Appendix B or as a separate appendix and a conclusion section added to it.

Response: Text has been added and revised in Section 1.1.3 and Appendix B to increase cohesion and to ensure essential information, assumptions, results, and conclusions are clear and transparent. Text describing PBPK model evaluation for the IRIS assessments of ethyl tertiary butyl ether and tert-butanol (U.S. EPA, 2017) has been added as a new appendix to the toxicological review (Appendix B.1.7.). Text in Section 1.1.3 and Appendix B have been revised to clarify that no models of tert-butanol have been created independently of other chemicals from which it arises as a metabolite.

### Charge Question 2c Choice of dose metric- Is the average concentration of tert-butanol in blood an appropriate choice for the dose metric?

[underlined: Key Recommendation]: The SAB recommended EPA state in the draft tert-butanol assessment how the average concentration of tert-butanol in blood was calculated given that the SAB agrees with use of this dose metric. The SAB also agreed with the use of an oral to inhalation extrapolation for tert-butanol.

[underlined: Response]: For non-continuous exposures the PBPK model was run for a number of days or weeks such that the predicted time course of tert-butanol in blood did not change with further days or weeks simulated. The average blood concentration of tert-butanol was calculated during the final periodic exposure. For uniformity, all scripts now calculate the average from episodic exposures on the basis of the final week of exposure (regardless of whether exposure is once per day or 5 times per week, since either exposure profile will be fully captured by averaging a 1-week time period). Details on how the average concentration of tert-butanol in blood was calculated has been added to Section 2.2.2, under subsection PODsfrom oral studies- use of PBPK model for route-to-route extrapolation.

## 3 Hazard Identification and Dose-Response Assessment- Noncancer

### Charge Question 3a Noncancer kidney toxicity (Sections 1.2.1, 1.3.1) identifies kidney effects as a potential human hazard of tert-butanol. EPA evaluated the evidence, including the role of alpha 2u-globulin and chronic progressive nephropathy: in accordance with EPA guidance (U.S. EPA. 1991a). Please comment on whether this conclusion is scientifically supported and clearly described

[underlined: Key Recommendation]: The SAB recommended EPA should provide a more thorough explanation for considering the enhancement of CPN as a kidney effect relevant to human hazard assessment. The SAB was unable to reach consensus on whether noncancer kidney effects should be considered a hazard relevant to humans based on the available evidence.

[underlined: Response]: In response to SAB comments, EPA consulted with pathologists at the National Toxicology Program (NTP) on the applicability of alpha 2u-globulin and the components of CPN in the evaluation of the human relevance of kidney effects (see Appendix D of the Supplemental Information). In consideration of the expert opinions of the pathologists, the assessment was revised to strengthen the explanation for considering the enhancement of CPN as a kidney effect relevant to human hazard (see Section 1.2.1). Briefly, following tert-butanol exposure, dose related increases in kidney weight and exacerbation of CPN were observed in both male and female rats. While tert-butanol exposure has been shown to act through an alpha-2u-globulin mechanism in male rats (which can exacerbate CPN, see Section 1.2.1), the dose related exacerbation of kidney effects in female rats cannot be explained by α2u-globulin. The NTP consultation (NIEHS, 2019) acknowledged existing literature and concluded that no analog to CPN occurs in humans (Hard et al., 2009) and that the etiology of CPN is unknown (Hard et al., 2013; Hard and Khan, 2004; Peter et al., 1986). However, many of the lesions observed in CPN are also observed in chronic kidney disease in humans (NIEHS, 2019; Lusco et al., 2016; Zoia et al., 2015; Frazier et al., 2012; Satirapoj et al., 2012). As summarized in the consultation, NTP concluded that due to the unknown etiology and lack of a clear pathogenesis “it cannot be ruled out that chemicals which exacerbate CPN in rats may have the potential to exacerbate disease processes in the human kidney”. A more thorough explanation for considering the enhancement of CPN as a kidney effect relevant to human hazard assessment has been added to Section 1.2.1.

### Charge Question 3b Noncancer at other sites (Sections 1.2.3-6, and 1.3.1) finds inadequate information to assess developmental neurodevelopmental, and reproductive toxicity. Please comment on whether these conclusions are scientifically supported and clearly described. If there are publicly available studies to associate other health outcomes with tert-butanol exposure: please identify them and outline the rationale for including them in the assessment

[underlined: Key Recommendation]: The SAB recommended EPA include contact dermatitis (Edwards and Edwards, 1982) in hazard identification as dermal exposure is a relevant route of exposure.

[underlined: Response]: Studies investigating the effects of acute dermal exposures are generally less pertinent for characterizing health hazards associated with chronic exposure. However, these studies were considered as sources of supporting health effects data (see Figure LS-1).

[underlined: Key Recommendation]: The SAB recommended EPA change the description to “minimal effects at otherwise toxic dose levels,” rather than “inadequate information to assess,” since the SAB believes there is an adequate amount of information, and only minimal effects have been shown, even at toxic dose levels.

[underlined: Response]: The description of noncancer effects was revised to be responsive to the SAB’s suggested language in Sections 1.2.3–1.2.6 and 1.3.1.

### Charge Question 3c Oral reference dose for noncancer kidney outcomes- Section 2.1 presents an oral reference dose of 4×10-1 mg/kg-day, based on increases in severity of nephropathy in female rats via drinking water (NTP, 1995). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative data set or approach would be more appropriate, please outline how such data might be used or how the approach might be developed

[underlined: Key Recommendation]: The SAB recommended EPA carefully reexamine the validity and applicability of the endpoints chosen and analyzed for the oral RfD for tert-butanol, including the potential for CPN and/or alpha-2u-globulin to serve as mechanism(s) of the kidney effects of tertbutanol, in light of SAB advice regarding consideration of the criteria for definition of CPN. The SAB was unable to reach a consensus as to whether the selection of nephropathy effects was appropriate. The SAB states that if EPA determines that increases in severity of nephropathy in female rats following tert-butanol in drinking water exposure remains the basis of the oral RfD, then the “SAB considers the derivation of the oral reference dose to be scientifically supported and its derivation clearly described”.

[underlined: Response]: As recommended by SAB, EPA carefully reexamined the kidney endpoints analyzed for the RfD with consideration of CPN and alpha 2u-globulin. EPA also consulted with pathologists at the National Toxicology Program (NTP) on the applicability of alpha 2u-globulin and the components of CPN in the evaluation of the human relevance of kidney effects (see Appendix D of the Supplemental Information). With this additional expert consultation, the assessment has been revised to clarify which effects were considered and to strengthen the justification regarding the human relevance of the observed kidney effects. For example, the assessment was revised to clarify that the kidney endpoints in males were not considered and the endpoints in females not confounded by alpha-2u-globin were considered (Section 1.2.1). See Integration of Kidney Effects in Section 1.2.1 of the Toxicological Review. See also response to Charge Question 3a.

[underlined: Key Recommendation]: The SAB recommended that the units need to be added to the tables in this section for completeness and interpretability. It would be useful to attempt a more integrated presentation of the current text, tables and graphs (i.e., the EPA should present key and related information/graphics on concurrent pages as much as possible). As currently laid out, the reader is forced to engage in a lot of page flipping in order to read the draft tert-butanol assessment, making it difficult to track information.

[underlined: Response]: Units have been added to the tables were missing, however, endpoints which display changes as “% change relative to control” are unitless. A more integrated presentation of text, table and figures is being implemented in future IRIS assessment templates.

[underlined: Key Recommendation]: The SAB recommended EPA include the outcomes of statistical analyses and their rationale in study selection choice in the draft tert-butanol assessment.

[underlined: Response]: Statistical significance as reported by the study authors was included in the appropriate evidence tables in Section 1.2.1. Key toxicological effects in the kidney were reported in eight studies derived from five references following oral exposure (Section 1.2.1). However, all kidney outcomes considered for dose response were derived from a single study (NTP, 1995). As described in Section 2.1.1, NTP, 1995 was identified as the most suitable for dose-response assessment considering the study duration, comprehensive reporting of outcomes, and multiple doses tested. Section 1.2.1 has been edited for clarity.

### Charge Question 3d Inhalation reference concentration for noncancer kidney outcomes- Section 2.2 presents an inhalation reference concentration of 5×100 mg/m3, based on increases in severity of nephropathy in female rats via drinking water (NTP, 1995), converted for inhalation exposure using a toxicokinetic model (Borghoff et al., 2016). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative data set or approach would be more appropriate, please outline how such data might be used or the approach might be developed

[underlined: Key Recommendation]: The SAB recommended EPA provide more detailed information about the specific application of the Borghoff et al. (2016)/U.S. EPA (2017) PBPK model used for route-to-route extrapolation to derive the inhalation RfC.

[underlined: Response]: Detailed information has been provided in Section 2.2 under PODs from oral studies- use of PBPK model for route-to-route extrapolation. This includes the choice of internal dose metric and uncertainty inherent in the use of a PBPK model for route-to route extrapolation. Section 2.2.4 provides an explanation for why preference was given to an RfC derived from the route-to-route extrapolated POD based on the chronic oral study over a POD from the sub chronic inhalation study.

[underlined: Key Recommendation]: The SAB recommended EPA provide more reporting of statistical analysis of individual studies to help clarify the appropriateness of inclusion/exclusion and use of studies.

[underlined: Response]: Statistical significance as reported by the study authors has been included in the appropriate evidence tables for each hazard section. The rationale for study selection and endpoint inclusion is discussed in Section 2.1.1.

## 4 Hazard Identification and Dose-Response Assessment- Cancer

### Charge Question 4a Cancer modes of action

#### (i) Cancer modes of action in the kidney-As described in section 1.2.1, kidney tumors were observed in male rats following tert-butanol exposure, and a mode-of-action involving alpha 2u-globulin and/or chronic progressive nephropathy was evaluated. The analysis, conducted in accordance with EPA’s guidance on renal toxicity and neoplasia in the male rat (U.S. EPA, 1991b), considered the kidney tumors in male rats to be relevant to human hazard identification. Please comment on whether this conclusion is scientifically supported

[underlined: Key Recommendation]: The SAB recommended EPA provide additional justification for the assumption that kidney tumors in male rats exposed to tert-butanol are relevant to humans.

Response: Based on EPA (U.S. EPA, 1991a) and IARC criteria (Capen et al., 1999) alpha 2u-globulin may contribute to kidney tumor formation in male rats exposed to tert-butanol (See section 1.2.1). However, evidence indicative of the alpha 2u-globulin process was not consistently observed across all studies. This observation suggests that tert-butanol may be a weak inducer of alpha 2u-globulin and its associated nephropathy. These inconsistencies are discussed in detail in Section 1.2.1. Although renal tubule hyperplasia and renal tumors are poorly correlated following tert-butanol exposure (NTP, 1995), there is a moderate correlation between CPN and renal tumor incidence in male rats suggesting a role for CPN in renal tumorigenesis. EPA requested an independent pathology consultation on the applicability of alpha 2u-globulin and CPN on kidney effects ((NIEHS, 2019); see Appendix D). NTP (NIEHS, 2019) concluded that the unknown etiology and poorly understood pathogenesis of CPN suggest that chemicals that exacerbate CPN may potentially induce kidney effects in humans. CPN also was exacerbated in female rats in the absence of renal tumor formation; therefore, it is also possible that other unknown mechanisms relevant to humans contribute to renal tumor formation in male rats. Additional justification for the human relevance of kidney tumors in male rats exposed to tert-butanol has been added in Section 1.2.1.

#### (ii) Cancer modes of action in the thyroid- As described in Section 1.2.2, thyroid tumors were observed in male and female mice following tert-butanol exposure, and an anti-thyroid mode-of-action was evaluated. The analysis, conducted in accordance with EPA’s guidance on thyroid follicular cell tumors in rodents (U.S. EPA, 1998), found the information inadequate to determine whether an anti-thyroid mode-of-action was operating and considered the thyroid follicular cell tumors in male and female mice to be relevant to humans. Please comment on whether this conclusion is scientifically supported

[underlined: Key Recommendations]: The SAB concurred with EPA’s determination that the mode of action for follicular tumors is unknown in male and female mice following tert-butanol exposure and should be considered relevant to humans in accordance with EPA policy. The SAB had no specific recommendations.

[underlined: Response]: No response needed.

### Charge Question 4b Cancer characterization-As described in Sections 1.2.1, 1.2.2, and 1.3.2, and in accordance with EPA’s cancer guidelines (U.S. EPA, 2005). the draft assessment concludes that there is suggestive evidence of carcinogenic potential for tert-butanol, based on thyroid follicular cell tumors in male and female B6C3F1 mice via drinking water and on renal tubule tumors in male F344 rats via drinking water. Please comment on whether this cancer descriptor is scientifically supported. If another cancer descriptor should be selected, please outline how it might be supported. Please comment on whether the “suggestive evidence” cancer descriptor is scientifically supported for all routes of exposure. If another cancer descriptor should be selected, please outline how it might be supported

[underlined: Key Recommendation]: The SAB agrees that there is scientific support for EPA’s conclusion that there is suggestive evidence of carcinogenic potential for tert-butanol for all routes of exposure. The SAB recommended EPA expand the scope and breadth of its discussion of potential modes and sites of action of tert-butanol on the thyroid.

[underlined: Response]: Discussion of modes of action for thyroid tumor formation was expanded in Section 1.2.2 and Appendix B to include studies that evaluate the mutagenic mode of action as recommended by EPA’s guidance on the assessment of thyroid cell tumors (U.S. EPA, 1998) (See section 1.2.2 and Appendix B). Information on other potential MOAs for tert-butanol in the thyroid is not currently available.

### Charge Question 4c Cancer toxicity values- Section 3 of EPA’s cancer guidelines (U.S. EPA, 2005) states: “When there is suggestive evidence, the Agency generally would not attempt a dose-response assessment, as the data generally would not support one, however, when the evidence includes a well-conducted study, quantitative analyses may be useful for some purposes, for example, providing a sense of the magnitude and uncertainty of potential risks, ranking potential hazards, or setting research priorities. In each case, the rationale for the quantitative analysis is explained, considering the uncertainty in the data and the suggestive nature of the weight of evidence.” Please comment on whether Section 2.3 of the draft assessment adequately explains the rationale for including a quantitative analysis given the “suggestive evidence” descriptor. Also comment whether the NTP (1995) study is a suitable basis for this quantitative analysis

[underlined: Key Recommendation]: The SAB recommended EPA provide a rationale for performing a quantitative analysis of thyroid tumors in Section 2.3 and suggested EPA consider potential worker and consumer exposures as a rationale. The SAB thought the dose-response modeling of thyroid tumors may not be useful because tumors were only observed at the highest dose; however, several committee members supported conducting a quantitative analysis to provide some sense of magnitude of potential carcinogenic risk. Therefore, the SAB recommended EPA refrain from conducting a quantitative analysis for tert-butanol carcinogenicity or explain the limitations of the analysis and clearly state the intended purpose is to simply provide some sense of the magnitude of potential risks.

[underlined: Response]: A rationale for performing a quantitative analysis of thyroid tumors has been added to Section 2.3, including potential worker and consumer exposures. One possible limitation in the interpretation of thyroid tumors that has been added to the discussion in the assessment is the increased incidence of thyroid tumors observed at highest dose tested and the possibility of nonlinear kinetics at the high dose. However, at the high dose level no increase in mortality was observed in female mice suggesting that the incidence of thyroid tumors was neither confounded by increased mortality nor exceeded the MTD (see added text in Section 1.2.2). Text was added to clearly state the intended purpose is to simply provide some sense of the magnitude of potential risks (See added text in Section 2.3).

### Charge Question 4d Oral slope factor for cancer- Section 2.3 presents an oral slope factor of 5 × 10-4 per mg/kg-day, based on thyroid tumors in male or female mice via drinking water (NTP, 1995). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative approach would be more appropriate, please outline how it might be developed

[underlined: Key Recommendation]: The SAB had no specific recommendations. The SAB was unable to reach a consensus on the suitability of the NTP (1995) drinking water study for developing an oral slope factor. Some reviewers were concerned about the potential lack of biological relevance due to the magnitude of the high dose and the possibility of non-linear kinetics at the high dose at which follicular tumors were observed. However, other members concluded that EPA’s choice for the oral slope factor for tert-butanol was scientifically supported.

[underlined: Response]: Justification (including strengths and limitations) for the derivation of an oral slope factor using thyroid tumors in mice was added in Section 1.3.2, as well as Sections 1.2.2 and 2.3 (see response to Question 4c).

### Charge Question 4e Inhalation unit risk for cancer- Section 2.4 presents no inhalation unit risk. The lack of a toxicokinetic model for mice precluded the use of the oral thyroid tumor data, and the inability to determine the relative contribution of alpha 2u - globulin nephropathy and other processes precluded the use of the oral renal tumor data from male rats. If an alternative approach would yield an inhalation unit risk estimate, please outline how it might be developed

[underlined: Key Recommendation]: The SAB had no specific recommendations.

[underlined: Response]: The SAB concurred with EPA’s decision to not develop an inhalation unit risk for tert-butanol.

### Charge Question 5 Susceptible Populations and Lifestages- As described in Section 1.3.3, the draft assessment found inadequate information to identify susceptible populations or lifestages, due to a lack of chemical-specific data. Please comment on whether this conclusion is scientifically supported and clearly described. If there are publicly available studies to identify1 other susceptible populations or lifestages, please identify them and outline their impact on the conclusions

[underlined: Key Recommendation]: The SAB recommended EPA correct the actual body weight for the treated group in Table 1-12 of the EPA’s draft tert-butanol assessment.

[underlined: Response]: Body weight is presented as percent change in Table 1–12. No errors were identified in the tables.

### Charge Question 6 Question on the Executive Summary- The Executive Summary is intended to provide a concise synopsis of the key findings and conclusions for a broad range of audiences. Please comment on whether the executive summary clearly and appropriately presents the major conclusions of the draft assessment

[underlined: Key Recommendations]: The SAB recommended EPA highlight the consequences of alternative choices for the final assessment in the Executive Summary, especially when these hinge on decisions made about the interpretation and relevance of key toxicity endpoints that have been contested (based on the history of public comment on the draft assessment).

[underlined: Response]: Text has been added to the Executive Summary to more clearly highlight the context around the interpretation and relevance of key endpoints such as the human relevance of the observed kidney effects (see Key issues Addressed in Assessment).

[underlined: Key Recommendations]: The SAB recommended EPA provide clarification for the Reference HSDB (HSDB, 2007) cited on page xiii. Reference HSDB (2007) is cited for tert-butanol in human milk. The two articles cited by HSDB (2007) do not provide evidence for the presence of tert-butanol in milk.

[underlined: Response]: The articles cited by the HSDB (2007) reference reported the results for 2-methyl-2-propanol, which is a synonym for tert-butanol; demonstrating the presence of tertbutanol in mother’s milk. This synonym for tert-butanol was included in Table LS-1 for clarification.

## Comments from two members of the Chartered SAB during the QA Review of the SAAB CAAC Peer Review Report

The Chartered SAB is tasked with conducting quality reviews of draft SAB reports to determine if they are ready for transmittal to the Administrator, reviewing whether the charge questions were adequately addressed by the CAAC, whether the report has technical errors or omissions, if the report is clear and logical, and if the CAAC recommendations in the report are supported by the body of the draft report. During this quality review of the draft SAB-CAAC report on the Draft IRIS assessments of ETBE and tert-butanol, two members of the chartered SAB (44 total members) disagreed with the CAAC regarding the recommendation for the cancer weight of evidence descriptors for ETBE and tert-butanol. These two members provided additional comments which were included as Appendix C of the Final SAB report. A summary and response to their comments, as they pertain to tert-butanol, are included below.

[underlined: Comment]: Two members of the chartered SAB disagreed with the SAB-CAAC’s support of EPA’s cancer weight of evidence descriptor of “suggestive evidence” for tert-butanol. They stated tertbutanol should be characterized as “insufficient evidence” (presumably analogous to EPA’s cancer weight of evidence descriptor for “inadequate evidence”) because thyroid follicular cell tumors were observed only in female mice at the highest exposure concentration in the NTP 2-year drinking water bioassay (NTP, 1995), a concentration they characterized as beyond the maximum tolerated dose (MTD) due to a 10-15% reduction in body weight. They concluded that the renal tubule adenomas are not relevant to humans because of poor survival rates in control animals in NTP 2-year drinking water bioassay (NTP, 1995), rat-specific MOA(s), and dose exceeds the MTD.

[underlined: Response]: The SAB-CAAC agreed with EPA’s determination of ‘suggestive evidence of carcinogenic potential” (See Charge Question 4b), as the database was consistent with this descriptor as illustrated in EPA’s 2005 Cancer Guidelines, based on thyroid follicular cell adenomas in female mice and thyroid follicular cell adenomas and carcinomas in male mice and renal tubule adenomas in male rats, although the SAB-CAAC did not reach consensus regarding the MOA(s) by which tertbutanol caused renal tubule adenomas in male rats. Briefly, an increase in thyroid adenomas was observed in female mice exposed to tert-butanol via drinking water (primarily at the high dose) with the incidence of combined adenomas and carcinomas of 2/58, 3/60, 2/59,9/59 at 0, 510, 1,020, and 2,110 mg/kg-d. The incidence of combined thyroid adenomas and carcinomas in male mice of 1/60, 0/59, 4/59, 2/57 at 0, 510,1,020, and 2,110 mg/kg-d was observed. The incidence of renal tubule adenomas and carcinomas observed by NTP in male rats was 8/50,13/50,19/50, 13/50 (or observed by Hard et al. (2011) in male rats was 4/50,13/50,18/50,12/50) at 0,90, 200, and 420 mg/kg-d. These thyroid and kidney tumors were statistically significantly increased by pairwise comparison (Fisher exact test, p ≤ 0.05) and by trend test (Cochran-Armitage trend test, p ≤ 0.05). Taken together, this evidence supports the descriptor of “suggestive evidence of carcinogenic potential”.

With regards to the comments on thyroid tumors, as discussed above, thyroid tumors were also observed in male mice. Regarding the assertion that the highest oral dose in the NTP (1995) study exceeded the MTD in mice, EPA’s 2005 Cancer Guidelines discuss the determination of an “excessively high dose” and describe the process as one of expert judgment which requires that “…adequate data demonstrate that the effects are solely the result of excessive toxicity rather than carcinogenicity of the tested agent.” In the case of thyroid follicular cell adenomas, the study authors noted that water consumption by exposed female mice was similar to controls and that no overt toxicity was observed. In addition, the final average body weight reduction in female mice at the highest dose was 12% (NTP, 1995) and female mice in the high dose group had higher rates of survival than control animals (see discussion and added text in Sections 1.2.2 and 2.3.1). The final average body weight reduction in male mice at the highest dose was 5% to 10% (NTP, 1995) and water consumption by exposed males was similar to controls, but survival was reduced at the highest dose and the tumor response in male mice was adjusted for early mortality. Thus, there is no evidence of exceedance of the MTD or that this is the cause of tumor development.

With regards to the comment on renal tubule adenomas and poor survival rates in the controls, EPA’s cancer guidelines (U.S. EPA, 2005) states that “the most relevant historical control data come from the same laboratory and the same supplier and are gathered within 2 or 3 years one way or the other of the study under review; other data should be used only with extreme caution.” Genetic drift in the laboratory strains and differences in pathology examination at different times and in different laboratories could affect comparability of historical and concurrent control data. In this case due to the lack of suitable historical control data, it is preferred to use concurrent controls to determine statistical significance of tumor incidence. Decreased survival in controls may be due in part to the increased severity of CPN in control animals (see Section 1.2.1). However, tumor increases were statistically significant in trend testing which accounted for mortality. With regards to the additional comments on MO A, the etiology of CPN is unknown and CPN is both a spontaneous and complex disease whose processes are affected by aging and strain specificity (NIEHS, 2019). Therefore, it is difficult to separate the effects of spontaneously occurring CPN from those effects on CPN induced by chemical exposure (see response to comments under Question 4a and discussion in Section 1.2.1.). With regards to the comment related to the MTD, in the case of renal tubule adenomas, the study authors did not report exposure-related overt toxicity in male rats or any changes in toxicokinetics at the middle or high doses. Mortality increased with increasing exposure (p = 0.001) over the 2-year exposure period; however increased mortality does not account for the highest tumor incidence occurring at the middle dose. Furthermore, the tumor incidence at the high dose in male rats, which had a final body weight reduction of 24% was not significantly different from controls (see discussion and added text in Section 1.2.1).

Discussion regarding the cancer descriptor for all routes of exposure, the rationale for deriving the oral slope factor, and the characterization of the cancer risk estimate can be found in Sections 1.3.2 and 2.3.1, and in response to comments under Charge Questions 4b, 4c, and 4d.

1 During the quality review by the Chartered SAB, 2 of the 44 members provided dissenting comments related to the cancer weight of evidence descriptors and the quantitative cancer risk estimates for ETBE and tBA. These comments were included as an appendix to the final SAB report and are summarized and addressed following the disposition of the SAB-CAAC recommendations below.

2 The SAB provided tiered recommendations: Tier 1 (key recommendations), Tier 2 (suggestions), and Tier 3 (future considerations).