# APPENDIX C DOSE-RESPONSE MODELING FOR THE DERIVATION OF REFERENCE VALUES FOR EFFECTS OTHER THAN CANCER AND THE DERIVATION OF CANCER RISK ESTIMATES

This appendix provides technical detail on dose-response evaluation and determination of points of departure (PODs) for relevant endpoints. The endpoints were modeled using EPA’s Benchmark Dose Software (BMDS), version 2.1.2. The preambles for the noncancer and cancer sections below describe the common practices used in evaluating the model fit and selecting the appropriate model for determining the POD as outlined in the Benchmark Dose Technical Guidance Document (U.S. EPA, 2000). In some cases, using alternative methods based on statistical judgment might be appropriate; exceptions are noted as necessary in the summary of the modeling results.

## C.1.1 Noncancer Endpoints

### Data Sets

Data sets selected for dose-response modeling are provided in Table C-1. In all cases, administered exposure was used in modeling the response data.

### Model Fit

All models were fit to the data using the maximum likelihood method. The following procedures were used, depending on whether data were dichotomous or continuous.

- For dichotomous models, the following parameter restrictions were applied: for the Log-Logistic model, restrict slope ≥1; for the Gamma and Weibull models, restrict power ≥1; and for the Multistage models, restrict beta values ≥0. Each model was tested for goodness of fit using a chi-square goodness-of-fit test (χ^2^ p-value <0.10 indicates lack of fit). Other factors also were used to assess model fit, including scaled residuals, visual fit, and adequacy of fit in the low dose region and near the benchmark response (BMR).
- For continuous models, the following parameter restrictions were applied: for Polynomial models, restrict beta values ≥0; and for the Hill, Power, and Exponential models, restrict power ≥1. Model fit was assessed by a series of tests. For each model, the homogeneity of the variances was tested first using a likelihood ratio test (BMDS Test 2). If Test 2 was not rejected (χ^2^ p-value ≥0.10), the model was fit to the data assuming constant variance. If Test 2 was rejected (χ^2^ p-value <0.10), the variance was modeled as a power function of the mean, and the variance model was tested for adequacy of fit using a likelihood ratio test (BMDS Test 3). For fitting models using either constant variance or modeled variance, models for the mean response were tested for adequacy of fit using a likelihood ratio test (BMDS Test 4, with χ^2^ p-value < 0.10 indicating inadequate fit). Other factors also were used to assess the model fit, including scaled residuals, visual fit, and adequacy of fit in the low-dose region and near the BMR.

Table C-1 Noncancer endpoints selected for dose-response modeling for tert-butanol

Endpoint/study | Species/sex | Doses and effect data
Kidney transitional epithelial hyperplasia NTP (1995) | Rat (F344)/female | Dose (mg/kg-d) | 0 | 180 | | 330 | | 650
Kidney transitional epithelial hyperplasia NTP (1995) | Rat (F344)/female | Incidence/total | 0/50 | 0/50 | | 3/50 | | 17/50
Increased absolute kidney weight NTP (1995) | Rat (F344)/female | Dose (mg/kg-d) | 0 | 180 | | 330 | | 650
Increased absolute kidney weight NTP (1995) | Rat (F344)/female | Mean ± SD (n) | 1.07 ± 0.09 (10) | 1.16 ± 0.10 (10) | | 1.27 ± 0.08 (10) | | 1.31 ± 0.09 (10)
Kidney inflammation NTP (1995) | Rat (F344)/female | Dose (mg/kg-d) | 0 | 180 | | 330 | | 650
Kidney inflammation NTP (1995) | Rat (F344)/female | Incidence/total | 2/50 | 3/50 | | 13/50 | | 17/50
Increased absolute kidney weight NTP (1997) | Rat (F344)/female | Concentration (mg/m^3^) | 0 | 406 | 825 | 1,643 | 3,274 | 6,369
Increased absolute kidney weight NTP (1997) | Rat (F344)/female | Mean ± SD (n) | 0.817 ± 0.136 (10) | 0.782 ± 0.063 (10) | 0.821 ± 0.061 (10) | 0.853 ± 0.045 (10) | 0.831 ± 0.054 (10) | 0.849 ± 0.038 (10)

### Model Selection

For each endpoint, the benchmark dose lower confidence limit (BMDL) estimate (95% lower confidence limit on the benchmark dose [BMD], as estimated by the profile likelihood method) and the Akaike’s information criterion (AIC) value were used to select a best-fit model among the models exhibiting adequate fit. If the BMDL estimates were “sufficiently close,” that is, differed by no more than threefold, the model selected was the one that yielded the lowest AIC value. If the BMDL estimates were not sufficiently close, the lowest BMDL was selected as the POD.

### Modeling Results

Below are tables summarizing the modeling results for the noncancer endpoints modeled.

Table C-2 Summary of BMD modeling results for kidney transitional epithelial hyperplasia in female F344 rats exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | BMD_10_ mg/kg-d | BMDL_10_ mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC | BMD_10_ mg/kg-d | BMDL_10_ mg/kg-d | Basis for model selection
Gamma | 0.83 | 91.41 | 409 | 334 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Logistic | 0.50 | 92.81 | 461 | 393 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Log-Logistic | 0.79 | 91.57 | 414 | 333 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Log-Probit | 0.89 | 91.19 | 400 | 327 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Multistage 3° | 0.92 | 89.73 | 412 | 339 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Probit | 0.62 | 92.20 | 439 | 372 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Weibull | 0.76 | 91.67 | 421 | 337 | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).
Dichotomous-Hill | N/A^b^ | 117.89 | Error^c^ | Error^c^ | Multistage 3rd-order model selected as best-fitting model based on lowest AIC with all BMDL values sufficiently close (BMDLs differed by less than threefold).

a Scaled residuals for selected model for doses 0, 180, 330, and 650 mg/m^3^ were 0.0, −0.664, 0.230, and 0.016, respectively.

b No available degrees of freedom to estimate a p-value.

c BMD and BMDL computation failed for the Dichotomous-Hill model.

Figure C-1 Plot of incidence by dose, with fitted curve for Multistage 3° model for kidney transitional epithelial hyperplasia in female F344 rats exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk; dose shown in mg/kg-day

====================================================================  
    Multistage Model. (Version: 3.2; Date: 05/26/2010)  
   Input Data File: M:\NCEA tert-butanol\BMD modeling\BMDS Output\20 NTP 1995b_Kidney transitional epithelial hyperplasia, female rats_Multi3_10.(d) 
   Gnuplot Plotting File: M:\NCEA tert-butanol\BMD modeling\BMDS Output\20 NTP 1995b_Kidney transitional epithelial hyperplasia, female rats_Multi3_10.plt 
        Mon May 09 18:31:33 2011 
 ====================================================================  
 
 [notes]  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
  The form of the probability function is:  
 
  P[response] = background + (1-background)*[1-EXP( 
         -beta1*dose^1-beta2*dose^2-beta3*dose^3)] 
 
  The parameter betas are restricted to be positive 
 
 
  Dependent variable = Incidence 
  Independent variable = Dose 
 
 Total number of observations = 4 
 Total number of records with missing values = 0 
 Total number of parameters in model = 4 
 Total number of specified parameters = 0 
 Degree of polynomial = 3 
 
 
 Maximum number of iterations = 250 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
         Default Initial Parameter Values  
           Background =      0 
            Beta(1) =      0 
            Beta(2) = 1.51408e-007 
            Beta(3) = 1.29813e-009 
 
 
      Asymptotic Correlation Matrix of Parameter Estimates 
 
      ( *** The model parameter(s) -Background  -Beta(1)  -Beta(2)   
         have been estimated at a boundary point, or have been specified by the user, 
         and do not appear in the correlation matrix ) 
 
        Beta(3) 
 
  Beta(3)      1 
 
 
 
                 Parameter Estimates 
 
                             95.0% Wald Confidence Interval 
    Variable     Estimate    Std. Err.   Lower Conf. Limit  Upper Conf. Limit 
   Background        0      *        *         * 
    Beta(1)        0      *        *         * 
    Beta(2)        0      *        *         * 
    Beta(3)   1.50711e-009      *        *         * 
 
* - Indicates that this value is not calculated. 
 
 
 
            Analysis of Deviance Table 
 
    Model   Log(likelihood) # Param's Deviance Test d.f.  P-value 
   Full model    -43.4002     4 
  Fitted model    -43.8652     1    0.9301   3     0.8182 
 Reduced model    -65.0166     1    43.2329   3     <.0001 
 
      AIC:     89.7304 
 
 
                 Goodness of Fit  
                                 Scaled 
   Dose   Est._Prob.  Expected  Observed   Size    Residual 
 ------------------------------------------------------------------------ 
  0.0000   0.0000     0.000   0.000     50    0.000 
 180.0000   0.0088     0.438   0.000     50    -0.664 
 330.0000   0.0527     2.636   3.000     50    0.230 
 650.0000   0.3389    16.946  17.000     50    0.016 
 
 Chi^2 = 0.49   d.f. = 3    P-value = 0.9200 
 
 
  Benchmark Dose Computation 
 
Specified effect =      0.1 
 
Risk Type    =   Extra risk  
 
Confidence level =      0.95 
 
       BMD =     411.95 
 
      BMDL =    338.618 
 
      BMDU =     469.73 
 
Taken together, (338.618, 469.73 ) is a 90   % two-sided confidence 
interval for the BMD

Table C-3 Summary of BMD modeling results for absolute kidney weight in female F344 rats exposed to tert-butanol in drinking water for 15 months (NTP, 1995); BMR = 10% relative deviation from control mean

Model^a^ | Goodness of fit | | BMD_10RD_ mg/kg-d | BMDL_10RD_ mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ mg/kg-d | BMDL_10RD_ mg/kg-d | Basis for model selection
Exponential (M2) Exponential (M3)^b^ | 0.0594 | −144.00 | 318 | 249 | The Exponential (M4) model was selected as the only model with adequate fit.
Exponential (M4) | 0.176 | −145.81 | 164 | 91.4 | The Exponential (M4) model was selected as the only model with adequate fit.
Exponential (M5) | N/A^c^ | −145.65 | 207 | 117 | The Exponential (M4) model was selected as the only model with adequate fit.
Hill | N/A^c^ | −145.65 | 202 | 119 | The Exponential (M4) model was selected as the only model with adequate fit.
Power^d^; Polynomial 3°^e^; Polynomial 2°^f^; Linear | 0.0842 | −144.70 | 294 | 224 | The Exponential (M4) model was selected as the only model with adequate fit.

a Constant variance case presented (BMDS Test 2 p-value = 0.852), selected model in bold; scaled residuals for selected model for doses 0, 180, 330, and 650 mg/kg-d were 0.21, −0.9, 0.94, −0.25, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary). The models in this row reduced to the Exponential (M2) model.

c No available degrees of freedom to calculate a goodness-of-fit value.

d For the Power model, the power parameter estimate was 1. The models in this row reduced to the Linear model.

e For the Polynomial 3° model, the b3 coefficient estimate was 0 (boundary of parameters space). The models in this row reduced to the Polynomial 2° model. For the Polynomial 3° model, the b3 and b2 coefficient estimates were 0 (boundary of parameters space). The models in this row reduced to the Linear model.

f For the Polynomial 2° model, the b2 coefficient estimate was 0 (boundary of parameters space). The models in this row reduced to the Linear model.

Figure C-2 Plot of mean response by dose, with fitted curve for Exponential (M4) model with constant variance for absolute kidney weight in female F344 rats exposed to tert-butanol in drinking water for 15 months (NTP, 1995); BMR = 10% relative deviation from control mean; dose shown in mg/kg-day

Exponential Model. (Version: 1.10; Date: 01/12/2015)

- The form of the response function is: Y[dose] = a *[c − (c − 1) *exp(−b * dose)].
- A constant variance model is fit.

Benchmark Dose Computation.

- BMR =10% Relative deviation
- BMD = 163.803
- BMDL at the 95% confidence level = 91.3614

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −4.84526 | −4.89115
rho | N/A | 0
a | 1.06808 | 1.0203
b | 0.00258011 | 0.00282085
c | 1.29013 | 1.35122
d | N/A | 1

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residuals
0 | 10 | 1.07 | 1.07 | 0.09 | 0.09 | 0.2112
180 | 10 | 1.16 | 1.18 | 0.1 | 0.09 | −0.8984
330 | 10 | 1.27 | 1.25 | 0.08 | 0.09 | 0.9379
650 | 10 | 1.31 | 1.32 | 0.09 | 0.09 | −0.2507

Likelihoods of Interest

Model | Log(likelihood) | # Parameters | AIC
A1 | 77.82307 | 5 | −145.6461
A2 | 78.21688 | 8 | −140.4338
A3 | 77.82307 | 5 | −145.6461
R | 62.21809 | 2 | −120.4362
4 | 76.90527 | 4 | −145.8105

Tests of Interest

Test | −2*log(Likelihood Ratio) | Test df | p-value
Test 1 | 32 | 6 | <0.0001
Test 2 | 0.7876 | 3 | 0.8524
Test 3 | 0.7876 | 3 | 0.8524
Test 6a | 1.836 | 1 | 0.1755

Table C-4 Summary of BMD modeling results for kidney inflammation in female rats exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | BMD_10_% mg/kg-d | BMDL_10_% mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC | BMD_10_% mg/kg-d | BMDL_10_% mg/kg-d | Basis for model selection
Gamma | 0.084 | 169.9 | 231 | 135 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
Logistic | 0.082 | 169.7 | 305 | 252 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
LogLogistic | 0.092 | 169.8 | 228 | 124 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
LogProbit | 0.243 | 167.6 | 254 | 200 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
Multistage 3° | 0.072 | 170.3 | 216 | 132 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
Probit | 0.108 | 169.2 | 285 | 235 | LogProbit was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
Weibull | 0.081 | 170.0 | 226 | 134
Dichotomous-Hill | N/A^b^ | 169.5 | 229 | 186

a Selected model in bold; scaled residuals for selected model for doses 0, 180, 330, and 650 mg/kg-d were −0.067, −0.700, 1.347, and −0.724, respectively.

b No available degrees of freedom to estimate a p-value.

Figure C-3 Plot of incidence by dose, with fitted curve for LogProbit model for kidney inflammation in female rats exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk; dose shown in mg/kg-day

====================================================================  
    Probit Model. (Version: 3.2; Date: 10/28/2009)  
   Input Data File: M:/NCEA tert-butanol/BMD modeling/BMDS Output/19 NTP 1995b_Kidney inflammation, female rats_LogProbit_10.(d)  
   Gnuplot Plotting File: M:/NCEA tert-butanol/BMD modeling/BMDS Output/19 NTP 1995b_Kidney inflammation, female rats_LogProbit_10.plt 
        Fri May 13 17:17:59 2011 
 ====================================================================  
 
 [notes]  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
  The form of the probability function is:  
 
  P[response] = Background 
        + (1-Background) * CumNorm(Intercept+Slope*Log(Dose)), 
 
  where CumNorm(.) is the cumulative normal distribution function 
 
 
  Dependent variable = Incidence 
  Independent variable = Dose 
  Slope parameter is restricted as slope >= 1 
 
  Total number of observations = 4 
  Total number of records with missing values = 0 
  Maximum number of iterations = 250 
  Relative Function Convergence has been set to: 1e-008 
  Parameter Convergence has been set to: 1e-008 
 
 
 
  User has chosen the log transformed model 
 
 
         Default Initial (and Specified) Parameter Values  
           background =     0.04 
           intercept =   -8.01425 
             slope =   1.18928 
 
 
      Asymptotic Correlation Matrix of Parameter Estimates 
 
      ( *** The model parameter(s) -slope   
         have been estimated at a boundary point, or have been specified by the user, 
         and do not appear in the correlation matrix ) 
 
       background  intercept 
 
background      1    -0.51 
 
 intercept    -0.51      1 
 
 
 
                 Parameter Estimates 
 
                             95.0% Wald Confidence Interval 
    Variable     Estimate    Std. Err.   Lower Conf. Limit  Upper Conf. Limit 
   background    0.0381743    0.0246892     -0.0102155      0.0865642 
   intercept     -6.82025     0.161407       -7.1366       -6.5039 
     slope        1        NA 
 
NA - Indicates that this parameter has hit a bound 
   implied by some inequality constraint and thus 
   has no standard error. 
 
 
 
            Analysis of Deviance Table 
 
    Model   Log(likelihood) # Param's Deviance Test d.f.  P-value 
   Full model    -80.4502     4 
  Fitted model    -81.8218     2    2.7432   2     0.2537 
 Reduced model    -92.7453     1    24.5902   3     <.0001 
 
      AIC:     167.644 
 
 
                 Goodness of Fit  
                                 Scaled 
   Dose   Est._Prob.  Expected  Observed   Size    Residual 
 ------------------------------------------------------------------------ 
  0.0000   0.0382     1.909   2.000     50    0.067 
 180.0000   0.0880     4.402   3.000     50    -0.700 
 330.0000   0.1859     9.295  13.000     50    1.347 
 650.0000   0.3899    19.495  17.000     50    -0.724 
 
 Chi^2 = 2.83   d.f. = 2    P-value = 0.2427 
 
 
  Benchmark Dose Computation 
 
Specified effect =      0.1 
 
Risk Type    =   Extra risk  
 
Confidence level =      0.95 
 
       BMD =    254.347 
 
      BMDL =    199.789

Table C-5 Summary of BMD modeling results for absolute kidney weight in female F344 rats exposed to tert-butanol via inhalation for 6 hours/day, 5 days/week for 13 weeks (NTP, 1997); BMR = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ mg/m^3^ | BMCL_10RD_ mg/m^3^ | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ mg/m^3^ | BMCL_10RD_ mg/m^3^ | Basis for model selection
Exponential (M2) Exponential (M3)^b^ | 0.0378 | −261.52 | 14,500 | 7,713 | No model adequately fit the data.
Exponential (M4) | 0.533 | −267.48 | Error^c^ | 0 | No model adequately fit the data.
Exponential (M5) | 0.374 | −265.71 | Error^c^ | 0 | No model adequately fit the data.
Hill | 0.227 | −265.57 | Error^c^ | Error^c^ | No model adequately fit the data.
Power | 0.0392 | −261.61 | 14,673 | 7,678 | No model adequately fit the data.
Polynomial 3°^d^; Polynomial 2°^e^; Linear | 0.0274 | −261.61 | 14,673 | 7,678 | No model adequately fit the data.
Polynomial 5° | 0.0274 | −261.61 | 14,673 | 7,569 | No model adequately fit the data.
Polynomial 4° | 0.0274 | −261.61 | 14,673 | 7,674 | No model adequately fit the data.

a Modeled variance case presented (BMDS Test 2 p-value = 1.90E−04, BMDS Test 3 p-value = 0.374), no model was selected as a best-fitting model.

b For the Exponential (M3) model, the estimate of d was 1 (boundary). The models in this row reduced to the Exponential (M2) model.

c BMC or BMCL computation failed for this model.

d For the Polynomial 3° model, the b3 coefficient estimate was 0 (boundary of parameters space). The models in this row reduced to the Polynomial 2° model. For the Polynomial 3° model, the b3 and b2 coefficient estimates were 0 (boundary of parameters space). The models in this row reduced to the Linear model.

e For the Polynomial 2° model, the b2 coefficient estimate was 0 (boundary of parameters space). The models in this row reduced to the Linear model.

Note: Graphs of the better fitting models are provided for illustration.

Figure C-4 Plot of mean response by concentration, with fitted curve for Hill model for absolute kidney weight in female F344 rats exposed to tert-butanol via inhalation for 6 hours/day, 5 days/week for 13 weeks (NTP, 1997); BMR = 10% relative deviation from the mean; concentration shown in mg/m^3^

Figure C-5 Plot of mean response by concentration, with fitted curve for Power model for absolute kidney weight in female F344 rats exposed to tert-butanol via inhalation for 6 hours/day, 5 days/week for 13 weeks (NTP,1997); BMR = 10% relative deviation from the mean; concentration shown in mg/m^3^

## C.1.2 Cancer Endpoints

### Data Sets

The cancer data sets selected for dose-response modeling are summarized in Table C-6. In all cases, administered exposure was used in modeling the response data. Because of the significant difference in survival in the high-dose male mice compared with the concurrent control, the Poly-3 procedure (Bailer and Portier, 1988) for adjusting tumor incidence rates for intercurrent mortality was used. The procedure is based on the observation that the cumulative incidence of tumors tends to increase with time raised to the second through the fourth powers for a large proportion of cases. In the Poly-3 procedure, for a study of T weeks’ duration, an animal that is removed from the study after t weeks (t < T) without a specified type of tumor of interest is given a weight of (t/T)^3^. An animal that survives until the terminal sacrifice at T weeks is assigned a weight of (T/T)^3^ = 1. An animal that develops the specific type of tumor of interest obviously lived long enough to develop the tumor and is assigned a weight of 1. The Poly-3 tumor incidence, adjusted for intercurrent mortality up to time T, is the number of animals in a dose group with the specified type of tumor divided by the sum of the weights (the effective number of animals at risk). The tumor incidences, adjusted using this procedure, also are provided in Table C-6.

### Model Fit

The Multistage model was fit to the cancer data sets. Model coefficients were restricted to be nonnegative (beta values ≥ 0) to estimate a monotonically increasing function. Each model was fit to the data using the maximum likelihood method and was tested for goodness of fit using a chi-square goodness-of-fit test (χ^2^ p-value < 0.05^1^ indicates lack of fit). Other factors were used to assess model fit, including scaled residuals, visual fit, and adequacy of fit in the low dose region and near the BMR.

For each endpoint, the BMDL estimate (95% lower confidence limit on the BMD, as estimated by the profile likelihood method) and AIC value were used to select a best-fit model from among the models exhibiting adequate fit. For the NTP (1995) and Hard et al. (2011) data, models were run with all doses included, as well as with the high dose dropped. Dropping the high dose resulted in a better fit to the data. Including the high dose caused the model to overestimate the control.

Table C-6 Cancer endpoints selected for dose-response modeling for tert-butanol

Endpoint/study | Species/sex | Doses and effect data
Thyroid
Thyroid follicular cell adenoma; NTP (1995) | B6C3F_1_ mice/female | Dose (mg/kg-d) | 0 | 510 | 1,020 | 2,110
Thyroid follicular cell adenoma; NTP (1995) | B6C3F_1_ mice/female | Incidence/total | 2/58 | 3/60 | 2/59 | 9/59
Thyroid follicular cell adenoma; NTP (1995) | B6C3F_1_ mice/male | Dose (mg/kg-d) | 0 | 540 | 1,040 | 2,070
Thyroid follicular cell adenoma; NTP (1995) | B6C3F_1_ mice/male | Incidence/total | 1/60 | 0/59 | 4/59 | 2/60
Thyroid follicular cell adenoma; NTP (1995) | B6C3F_1_ mice/male | Incidence/Poly-3 adjusted total | 1/50 | 0/50 | 4/51 | 2/35
Kidney^a^
Renal tubule adenoma or carcinoma; NTP (1995) | Rat (F344)/Male | Dose (mg/kg-d) | 0 | 90 | 200 | 420
Renal tubule adenoma or carcinoma; NTP (1995) | Rat (F344)/Male | Incidence/total | 8/50 | 13/50 | 19/50 | 13/50
Renal tubule adenoma or carcinoma; NTP (1995) | Rat (F344)/Male | Incidence/total | 8/50 | 13/50 | 19/50 | 13/50
Renal tubule adenoma or carcinoma; NTP (1995) | Rat (F344)/Male | Incidence/total | 8/50 | 13/50 | 19/50 | 13/50
Renal tubule adenoma or carcinoma; hard reanalysis; NTP (1995); Hard et al. (2011) | Rat (F344)/Male | Dose (mg/kg-d) | 0 | 90 | 200 | 420
Renal tubule adenoma or carcinoma; hard reanalysis; NTP (1995); Hard et al. (2011) | Rat (F344)/Male | Incidence/total | 4/50 | 13/50 | 18/50 | 12/50
Renal tubule adenoma or carcinoma; hard reanalysis; NTP (1995); Hard et al. (2011) | Rat (F344)/Male | Incidence/total | 4/50 | 13/50 | 18/50 | 12/50
Renal tubule adenoma or carcinoma; hard reanalysis; NTP (1995); Hard et al. (2011) | Rat (F344)/Male | Incidence/total | 4/50 | 13/50 | 18/50 | 12/50

a Endpoint presented if kidney tumors are acceptable for quantitation.

Table C-7 Summary of the oral slope factor derivations

Tumor | Species/sex | Selected model | BMR (%) | BMD mg/kg-d | POD = BMDL mg/kg-d | BMDL_HED_^a^ mg/kg-d | Slope factor^b^ mg/kg-d^−1^
Thyroid
Thyroid follicular cell adenoma | Female B6C3F_1_ mouse | 3° Multistage | 10 | 2,002 | 1,437 | 201 | 5 × 10^−4^
Kidney^c^
Renal tubule adenoma or carcinoma | Male F344 rat; dose as administered | 1° multistage (high dose dropped) | 10 | 70 | 42 | 10.1 | 1 × 10^−2^
Renal tubule adenoma or carcinoma [Hard et al. (2011) reanalysis] | Male F344 rat; dose as administered | 1° multistage (high dose dropped) | 10 | 54 | 36 | 8.88 | 1 × 10^−2^

HED = human equivalent dose.

a HED PODs were calculated using BW^3/4^ scaling (U.S. EPA, 2011).

b Human equivalent slope factor = 0.1/BMDL_10HED_.

c Alternative endpoint if kidney tumors are acceptable for quantitation.

### Modeling Results

Table C-8 Summary of BMD modeling results for thyroid follicular cell adenomas in female B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | BMD_10_%^c^ mg/kg-d | BMDL_10_%^c^ mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC^b^ | BMD_10_%^c^ mg/kg-d | BMDL_10_%^c^ mg/kg-d | Basis for model selection
Three | 0.75 | 113.665 | 2,002 | 1,437 | Multistage 3° was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
Two | 0.36 | 115.402 | 2,186 | 1,217 | Multistage 3° was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).
One | 0.63 | 114.115 | 1,987 | 1,378 | Multistage 3° was selected on the basis of the lowest AIC with all BMDL values for fitting models being sufficiently close (BMDLs differed by less than threefold).

a Selected (best-fitting) model shown in boldface type.

b AIC = Akaike information criterion.

c Confidence level = 0.95.

Figure C-6 Plot of incidence by dose, with fitted curve for Multistage 3° model for thyroid follicular cell adenomas in female B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 10% extra risk; dose shown in mg/kg-day

====================================================================  
      Multistage Cancer Model. (Version: 1.9;  Date: 05/26/2010)  
     Input Data File: M:\NCEA t-Butanol\BMD modeling\BMDS Output\29 NTP 1995b_Thyroid follicular cell adenoma, female mice_MultiCanc3_10.(d) 
     Gnuplot Plotting File: M:\NCEA t-Butanol\BMD modeling\BMDS Output\29 NTP 1995b_Thyroid follicular cell adenoma, female mice_MultiCanc3_10.plt 
        Fri May 13 15:22:18 2011 
 ====================================================================  
 
 [notes]  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1-beta2*dose^2-beta3*dose^3)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Incidence 
   Independent variable = Dose 
 
 Total number of observations = 4 
 Total number of records with missing values = 0 
 Total number of parameters in model = 4 
 Total number of specified parameters = 0 
 Degree of polynomial = 3 
 
 
 Maximum number of iterations = 250 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =    0.0347373 
                        Beta(1) =            0 
                        Beta(2) =            0 
                        Beta(3) = 1.36917e-011 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Beta(1)    -Beta(2)    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
             Background      Beta(3) 
 
Background            1        -0.53 
 
   Beta(3)        -0.53            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background        0.0361209            *                *                  * 
        Beta(1)                0            *                *                  * 
        Beta(2)                0            *                *                  * 
        Beta(3)     1.31301e-011            *                *                  * 
 
* - Indicates that this value is not calculated. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -54.5437         4 
   Fitted model        -54.8326         2      0.577881      2          0.7491 
  Reduced model        -58.5048         1       7.92235      3         0.04764 
 
           AIC:         113.665 
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0361         2.095     2.000          58       -0.067 
  510.0000     0.0378         2.268     3.000          60        0.496 
 1020.0000     0.0495         2.918     2.000          59       -0.551 
 2110.0000     0.1480         8.730     9.000          59        0.099 
 
 Chi^2 = 0.56      d.f. = 2        P-value = 0.7544 
 
 
   Benchmark Dose Computation 
 
Specified effect =            0.1 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        2002.03 
 
            BMDL =        1436.69 
 
            BMDU =        3802.47 
 
Taken together, (1436.69, 3802.47) is a 90     % two-sided confidence 
interval for the BMD 
 
Multistage Cancer Slope Factor =  6.96043e-005

Table C-9 Summary of BMD modeling results for thyroid follicular cell adenomas or carcinomas in male B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 5% extra risk

Model^a^ | Goodness of fit | | BMD_5_% mg/kg-d | BMDL_5_%^c^ mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC^b^ | BMD_5_% mg/kg-d | BMDL_5_%^c^ mg/kg-d | Basis for model selection
One, two, three | 0.202 | 61.6 | 1,788 | 787 | Multistage 1° was selected. Only form of multistage that resulted; fit adequate.

a Selected (best-fitting) model shown in boldface type.

b AIC = Akaike information criterion.

c Confidence level = 0.95.

Figure C-7 Plot of incidence by dose, with fitted curve for Multistage 1° model for thyroid follicular cell adenomas or carcinomas in male B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years (NTP, 1995); BMR = 5% extra risk; dose shown in mg/kg-day

 ====================================================================  
      Multistage Model. (Version: 3.4;  Date: 05/02/2014)  
     Input Data File: C:/Users/KHOGAN/BMDS/BMDS260/Data/msc_TBA NTP1995 MMthyroid tumors poly3_Msc1-BMR05.(d)   
     Gnuplot Plotting File:  C:/Users/KHOGAN/BMDS/BMDS260/Data/msc_TBA NTP1995 MMthyroid tumors poly3_Msc1-BMR05.plt 
        Fri Jun 05 11:02:14 2015 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
 
 Total number of observations = 4 
 Total number of records with missing values = 0 
 Total number of parameters in model = 2 
 Total number of specified parameters = 0 
 Degree of polynomial = 1 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =    0.0164855 
                        Beta(1) = 2.58163e-005 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
             Background      Beta(1) 
 
Background            1        -0.56 
 
   Beta(1)        -0.56            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background        0.0149284        0.0144833          -0.0134584           0.0433151 
        Beta(1)     2.86952e-005     1.99013e-005       -1.03105e-005         6.7701e-005 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -26.5891         4 
   Fitted model         -28.808         2       4.43785      2          0.1087 
  Reduced model        -29.8255         1       6.47273      3         0.09074 
 
           AIC:          61.616 
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0149         0.746     1.000      50.000        0.296 
  540.0000     0.0301         1.504     0.000      50.000       -1.245 
 1040.0000     0.0439         2.238     4.000      51.000        1.204 
 2070.0000     0.0717         2.511     2.000      35.000       -0.335 
 
 Chi^2 = 3.20      d.f. = 2        P-value = 0.2019 
 
 
   Benchmark Dose Computation 
 
Specified effect =           0.05 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        1787.52 
 
            BMDL =        787.153 
 
 
BMDU did not converge for BMR = 0.050000 
BMDU calculation failed 
            BMDU = Inf

Table C-10 Summary of BMD modeling results for thyroid follicular cell adenomas or carcinomas in male B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years, high dose omitted (NTP, 1995); BMR = 5% extra risk

Model^a^ | Goodness of fit | | BMD_5_% mg/kg-d | BMDL_5_%^c^ mg/kg-d | Basis for model selection
Model^a^ | p-value | AIC^b^ | BMD_5_% mg/kg-d | BMDL_5_%^c^ mg/kg-d | Basis for model selection
One stage | 0.105 | 46.0 | 1,341 | 538 | Multistage 2° was selected based on lowest AIC.
Two stage | 0.174 | 44.9 | 1,028 | 644 | Multistage 2° was selected based on lowest AIC.

a Selected (best-fitting) model shown in boldface type.

b AIC = Akaike information criterion.

c Confidence level = 0.95.

Figure C-8 Plot of incidence by dose, with fitted curve for Multistage 2° model for thyroid follicular cell adenomas or carcinomas in male B6C3F_1_ mice exposed to tert-butanol in drinking water for 2 years, high dose omitted (NTP, 1995); BMR = 5% extra risk; dose shown in mg/kg-day

====================================================================  
      Multistage Model. (Version: 3.4;  Date: 05/02/2014)  
     Input Data File: C:/Users/KHOGAN/BMDS/BMDS260/Data/msc_TBA NTP1995 MMthyroid tumors poly3 -h_Msc2-BMR05.(d)   
     Gnuplot Plotting File:  C:/Users/KHOGAN/BMDS/BMDS260/Data/msc_TBA NTP1995 MMthyroid tumors poly3 -h_Msc2-BMR05.plt 
        Fri Jun 05 11:18:05 2015 
 ====================================================================  
 
 BMDS_Model_Run  
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~ 
  
   The form of the probability function is:  
 
   P[response] = background + (1-background)*[1-EXP( 
                 -beta1*dose^1-beta2*dose^2)] 
 
   The parameter betas are restricted to be positive 
 
 
   Dependent variable = Effect 
   Independent variable = Dose 
 
 Total number of observations = 3 
 Total number of records with missing values = 0 
 Total number of parameters in model = 3 
 Total number of specified parameters = 0 
 Degree of polynomial = 2 
 
 
 Maximum number of iterations = 500 
 Relative Function Convergence has been set to: 1e-008 
 Parameter Convergence has been set to: 1e-008 
 
 
 
                  Default Initial Parameter Values   
                     Background =   0.00347268 
                        Beta(1) =            0 
                        Beta(2) = 6.65923e-008 
 
 
           Asymptotic Correlation Matrix of Parameter Estimates 
 
           ( *** The model parameter(s)  -Beta(1)    
                 have been estimated at a boundary point, or have been specified by the user, 
                 and do not appear in the correlation matrix ) 
 
             Background      Beta(2) 
 
Background            1        -0.34 
 
   Beta(2)        -0.34            1 
 
 
 
                                 Parameter Estimates 
 
                                                         95.0% Wald Confidence Interval 
       Variable         Estimate        Std. Err.     Lower Conf. Limit   Upper Conf. Limit 
     Background         0.011558        0.0114911           -0.010964           0.0340801 
        Beta(1)                0               NA 
        Beta(2)     4.84624e-008     3.15009e-008       -1.32781e-008        1.10203e-007 
 
NA - Indicates that this parameter has hit a bound 
     implied by some inequality constraint and thus 
     has no standard error. 
 
 
 
                        Analysis of Deviance Table 
 
       Model      Log(likelihood)  # Param's  Deviance  Test d.f.   P-value 
     Full model        -18.9229         3 
   Fitted model        -20.4481         2       3.05031      1         0.08072 
  Reduced model        -21.9555         1        6.0651      2         0.04819 
 
           AIC:         44.8962 
 
 
                                  Goodness  of  Fit  
                                                                 Scaled 
     Dose     Est._Prob.    Expected    Observed     Size       Residual 
  ------------------------------------------------------------------------ 
    0.0000     0.0116         0.578     1.000      50.000        0.558 
  540.0000     0.0254         1.271     0.000      50.000       -1.142 
 1040.0000     0.0620         3.164     4.000      51.000        0.485 
 
 Chi^2 = 1.85      d.f. = 1        P-value = 0.1735 
 
 
   Benchmark Dose Computation 
 
Specified effect =           0.05 
 
Risk Type        =      Extra risk  
 
Confidence level =           0.95 
 
             BMD =        1028.79 
 
            BMDL =        644.475 
 
 
BMDU did not converge for BMR = 0.050000 
BMDU calculation failed 
            BMDU =        14661.6 
 
Cancer Slope Factor =  7.75825e-005

Table C-11 Summary of BMD modeling results for renal tubule adenoma or carcinoma in male F344 rats exposed to tert-butanol in drinking water for 2 years modeled with administered dose units and including all dose groups (NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Three Two | 0.0806 | −0.989, 0.288, 1.719, and −1.010 | 233.94 | 294 | 118 | Multistage 2° is selected as the most parsimonious model of adequate fit.
One | 0.0806 | −0.989, 0.288, 1.719, and −1.010 | 233.94 | 294 | Error^b^ | Multistage 2° is selected as the most parsimonious model of adequate fit.

a Selected model in bold.

b BMD or BMDL computation failed for this model.

Figure C-9 Plot of incidence by dose, with fitted curve for Multistage 2° model for renal tubule adenoma or carcinoma in male F344 rats exposed to tert-butanol in drinking water for 2 years modeled with administered dose units and including all dose groups (NTP, 1995); BMR = 10% extra risk; dose shown in mg/kg-day

Multistage Cancer Model. (Version: 1.9; Date: 05/26/2010)

- The form of the probability function is: P [response] = background + (1-background)* [1-EXP(-beta1*dose^∧^1-beta2*dose^∧^ 2…)]
- The parameter betas are restricted to be positive

Benchmark Dose Computation.

- BMR = 10% Extra risk
- BMD = 293.978
- BMDL at the 95% confidence level = 117.584
- BMDU at the 95% confidence level = 543384000
- Taken together, (117.584, 543384000) is a 90% two-sided confidence interval for the BMD Multistage Cancer Slope Factor = 0.000850453

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0.217704 | 0.2335
Beta(1) | 0.000358397 | 0.000268894
Beta(2) | 0 | 0

Analysis of Deviance Table

Model | Log(likelihood) | # Parameters | Deviance | Test df | p-value
Full model | −112.492 | 4
Fitted model | −114.97 | 2 | 4.95502 | 2 | 0.08395
Reduced model | −115.644 | 1 | 6.30404 | 3 | 0.09772

AIC = 233.94

Goodness-of-Fit Table

Dose | Estimated Probability | Expected | Observed | Size | Scaled residuals
0 | 0.2177 | 10.885 | 8 | 50 | −0.989
90 | 0.2425 | 12.127 | 13 | 50 | 0.288
200 | 0.2718 | 13.591 | 19 | 50 | 1.719
420 | 0.327 | 16.351 | 13 | 50 | −1.01

χ^2^ = 5.04

df = 2

p-value = 0.0806

Table C-12 Summary of BMD modeling results for renal tubule adenoma or carcinoma in male F344 rats exposed to tert-butanol in drinking water for 2 years modeled with administered dose units and excluding high-dose group (NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | | BMD_10Pct_ (mg/kg-d) | BMDL_10Pct_ mg/kg-d | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMD_10Pct_ (mg/kg-d) | BMDL_10Pct_ mg/kg-d | Basis for model selection
Two | N/A^b^ | 0.000, −0.000, and −0.000 | 173.68 | 75.6 | 41.6 | Multistage 1° was selected as the only adequately-fitting model available
One | 0.924 | 0.031, −0.078, and 0.045 | 171.69 | 70.1 | 41.6 | Multistage 1° was selected as the only adequately-fitting model available

a Selected model in bold.

b No available degrees of freedom to calculate a goodness-of-fit value.

Figure C-10 Plot of incidence by dose, with fitted curve for Multistage 1° model for renal tubule adenoma or carcinoma in male F344 rats exposed to terř-butanol in drinking water for 2 years modeled with administered dose units and excluding high-dose group (NTP, 1995); BMR = 10% extra risk.; dose shown in mg/kg-day

Multistage Cancer Model. (Version: 1.9; Date: 05/26/2010)

- The form of the probability function is: P [response] = background + (1-background)* [1-EXP(-beta1*dose^∧^1-beta2*dose^∧^ 2…)]
- The parameter betas are restricted to be positive

Benchmark Dose Computation.

- BMR = 10% Extra risk
- BMD = 70.1068
- BMDL at the 95% confidence level = 41.5902
- BMDU at the 95% confidence level = 203.311
- Taken together, (41.5902, 203.311) is a 90% two-sided confidence interval for the BMD Multistage Cancer Slope Factor = 0.00240441

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0.158399 | 0.156954
Beta(1) | 0.00150286 | 0.0015217

Analysis of Deviance Table

Model | Log(likelihood) | # Parameters | Deviance | Test df | p-value
Full model | −83.8395 | 3
Fitted model | −83.8441 | 2 | 0.00913685 | 1 | 0.9238
Reduced model | −86.9873 | 1 | 6.29546 | 2 | 0.04295

AIC = 171.688

Goodness-of-Fit Table

Dose | Estimated Probability | Expected | Observed | Size | Scaled residuals
0 | 0.1584 | 7.92 | 8 | 50 | 0.031
90 | 0.2649 | 13.243 | 13 | 50 | −0.078
200 | 0.3769 | 18.844 | 19 | 50 | 0.045

χ^2^ = 0.01

df = 1

p-value = 0.9239

Table C-13 Summary of BMD modeling results for renal tubule adenoma or carcinoma in male F344 rats exposed to tert-butanol in drinking water for 2 years modeled with administered dose units and including all dose groups; reanalyzed data (Hard et al., 2011; NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Three; Two; One | 0.0117 | −1.476, 1.100, 1.855, and −1.435 | 218.68 | 184 | 94.8 | No model fit the data.

a No model was selected as a best-fitting model.

Table C-14 Summary of BMD modeling results for renal tubule adenoma or carcinoma in male F344 rats exposed to tert-butanol in drinking water for 2 years modeled with administered dose units and excluding high-dose group; reanalyzed data (Hard et al., 2011; NTP, 1995); BMR = 10% extra risk

Model^a^ | Goodness of fit | | | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMD_10Pct_ mg/kg-d | BMDL_10Pct_ mg/kg-d | Basis for model selection
Two One | 0.572 | −0.141, 0.461, and −0.296 | 154.84 | 54.2 | 36.3 | Multistage 1° was selected as the most parsimonious model of adequate fit.

a Selected model in bold.

Figure C-11 Plot of incidence by dose, with fitted curve for Multistage 1° model for renal tubule adenoma or carcinoma in male F344 rats exposed to terř-butanol in drinking water for 2 years modeled with administered dose units and excluding high-dose group; reanalyzed data (Hard et al., 2011; NTP, 1995); BMR = 10% extra risk; dose shown in mg/kg-day

Multistage Cancer Model. (Version: 1.9; Date: 05/26/2010)

- The form of the probability function is: P [response] = background + (1-background)* [1-EXP(-beta1*dose^∧^1-beta2*dose^∧^ 2…)]
- The parameter betas are restricted to be positive

Benchmark Dose Computation.

- BMR = 10% Extra risk
- BMD = 54.1642
- BMDL at the 95% confidence level = 36.3321
- BMDU at the 95% confidence level = 101.125
- Taken together, (36.3321,101.125) is a 90% two-sided confidence interval for the BMD Multistage Cancer Slope Factor = 0.00275239

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0.0855815 | 0.0981146
Beta(1) | 0.00194521 | 0.00179645

Analysis of Deviance Table

Model | Log(likelihood) | # Parameters | Deviance | Test df | p-value
Full model | −75.2622 | 3
Fitted model | −75.4201 | 2 | 0.315716 | 1 | 0.5742
Reduced model | −81.4909 | 1 | 12.4574 | 2 | 0.001972

AIC = 154.84

Goodness-of-Fit Table

Dose | Estimated probability | Expected | Observed | Size | Scaled residuals
0 | 0.0856 | 4.279 | 4 | 50 | −0.141
90 | 0.2324 | 11.622 | 13 | 50 | 0.461
200 | 0.3803 | 19.015 | 18 | 50 | −0.296

χ^2^ = 0.32

df = 1

p-value = 0.5715

1 A significance level of 0.05 is used for selecting cancer models because the model family (Multistage) is selected a priori (U.S. EPA, 2000).