# APPENDIX B INFORMATION IN SUPPORT OF HAZARD IDENTIFICATION AND DOSE-RESPONSE ANALYSIS

## B.1 TOXICOKINETICS

Little information is available on the absorption, distribution, metabolism, or excretion of tert-butyl alcohol (tert-butanol) in humans. The studies identified for this Toxicological Assessment were conducted in conjunction with methyl tert-butyl ether (MTBE) or ethyl tert-butyl ether (ETBE) because tert-butanol is a metabolite of both compounds. Several studies examining some aspect of the toxicokinetic behavior of tert-butanol in animals have been identified. Many of these toxicokinetic studies were carried out in conjunction with other specific endpoints (e.g., developmental). ARCO (1983) did not observe differences in the pharmacokinetics of tert-butanol following either oral (i.e., gavage) or inhalation exposure. Although some information is available for both oral and inhalation exposures, many studies administered tert-butanol via intraperitoneal (i.p.) or intravenous (i.v.) injection. Although these studies do not inform the absorption of tert-butanol, they can provide information on its distribution, metabolism, and excretion.

### B.1.1 Absorption

Toxicity data on tert-butanol submitted by industry to the U.S. Environmental Protection Agency (EPA) under Section 8(e) of the Toxic Substances Control Act and other reporting requirements indicate that tert-butanol is rapidly absorbed after oral administration. Very little of the administered dose was excreted in the feces of rats, indicating that 99% of the compound was absorbed. Comparable blood levels of tert-butanol and its metabolites have been observed after acute oral (350 mg/kg) or inhalation (6,060 mg/m^3^ for 6 hours) exposure in male Sprague-Dawley rats (ARCO, 1983): the absorption rate after inhalation exposure could not be determined, however, because the blood was saturated with radioactivity after 6 hours of exposure to 6,060 mg/m^3^. In another study (Faulkner et al., 1989), blood concentrations indicated that absorption was complete at 1.5 hours following the last of six oral gavage doses of 10.5 mmoles tert-butanol/kg (twice daily) in female C57BL/6J mice. There was an apparent zero-order decline in tert-butanol concentration for most of the elimination phase, and no differences in absorption or elimination rates were observed between mice on a repeated dosing regimen and mice administered equivalent volumes of tap water every 12 hours before administration of a single dose of 10.5 mmoles tert-butanol/kg. The study therefore concluded that previous exposures did not affect the absorption or elimination of tert-butanol (Faulkner et al., 1989).

### B.1.2 Distribution

The available animal data suggest that tert-butanol is distributed throughout the body following oral, inhalation, and i.v. exposures (Poet et al., 1997; Faulkner et al., 1989; ARCO, 1983). Nihlén et al. (1995) calculated partition coefficients for tert-butanol using blood from human volunteers and available information about the relative content of water and fat in each tissue. The calculated tissue:blood partition coefficients for tert-butanol were slightly above 1 (from 1.02 to 1.06) for most tissues, except for fat:blood, which had a partition coefficient of 0.646. The same study evaluated the partition coefficients of three oxygenated ethers, including MTBE and ETBE, which are metabolized to tert-butanol (see Section B.1.4). The study concluded that, although tert-butanol preferentially distributes in body water, the ethers distribute uniformly throughout the body with a preference for fatty tissues (Nihlén et al., 1995).

In a study aimed at determining whether tert-butanol (or metabolites) can bind to alpha 2u-globulin, Williams and Borghoff (2001) exposed F344 rats to a single gavage dose of 500 mg/kg ^14^C-tert-butanol and evaluated tissue levels at 12 hours. They found the radiolabel in three tissues (kidney, liver, and blood) in both sexes, but male rats retained more of the tert-butanol equivalents than females (Williams and Borghoff, 2001). Radioactivity was found in the low-molecular-weight protein fraction isolated from the kidney cytosol in male rats but not in female rats, indicating that tert-butanol, or one of its metabolites, was bound to alpha 2u-globulin. Further analysis determined that tert-butanol, and not its metabolite acetone, was bound. Most tert-butanol in the kidney cytosol was eluted as the free compound in both males and females, but a small amount was associated with the high-molecular-weight protein fraction in both males and females. In another study on alpha 2u-globulin nephropathy, Borghoff et al. (2001) found similar results after F344 rats were exposed to 0, 250,450, or 1,750 ppm tert-butanol by inhalation for 8 consecutive days (with tissue levels measured at 2,4, 6, 8, and 16 hours postexposure). Male rat tert-butanol kidney-to-blood ratios were significantly elevated over ratios in females at all dose levels and exposure durations. Although the female tert-butanol kidney-to-blood ratio remained similar with both duration and concentration, the male tert-butanol kidney-to-blood ratio increased with duration. The liver-to-blood ratios were similar, regardless of exposure duration, concentration, or sex. Both of these studies indicate distribution of tert-butanol to the liver and kidney, with kidney retention of tert-butanol in the male rat.

### B.1.3 Metabolism

A general metabolic scheme for tert-butanol, illustrating the biotransformation in rats and humans, is shown in Figure B-1. Urinary metabolites of tert-butanol in a human male volunteer who ingested a gelatin capsule containing 5 mg/kg [^13^C]-tert-butanol were reported to be 2-methyl-1,2-propanediol (MPD) and 2-hydroxyisobutyrate [HBA; Bernauer et al. (1998)]. Minor metabolites of unconjugated tert-butanol,tert-butanol glucuronides, and traces of the sulfate conjugate also were detected. The study was approved by an ethical review board, but no information regarding informed consent was reported. In the same study, HBA, MPD, and tert-butanol sulfate were identified as major metabolites in rats, whereas acetone, tert-butanol, and tert-butanol glucuronides were identified as minor metabolites (Bernauer et al., 1998). Baker et al. (1982) found that tert-butanol was a source of acetone, but acetone production might have been stimulated from other sources.

Figure B-1 Biotransformation of tert-butanol in rats and humans

Sources: NSF International (2003), ATSDR (1996), Bernauer et al. (1998), Amberg et al. (1999), and Cederbaum and Cohen (1980).

No studies identified specific enzymes responsible for the biotransformation of tert-butanol. Using a purified enzyme from Sprague-Dawley rats or whole-liver cytosol from Wistar rats, alcohol dehydrogenase had negligible or no activity toward tert-butanol (Videla et al., 1982; Arslanian et al., 1971). Other in vitro studies have implicated the liver microsomal mixed function oxidase (MFO) system, namely cytochrome P450 [CYP450; Cederbaum et al. (1983); Cederbaum and Cohen (1980)]. In the 1983 study, incubation of tert-butanol at 35 mM with Sprague-Dawley rat liver microsomes and a reduced nicotinamide adenine dinucleotide phosphate (NADPH)-generating system resulted in formaldehyde production at a rate of approximately 25 nmoles/mg protein/30 minutes. According to the study authors, the amount of formaldehyde generated from tert-butanol was approximately 30% of the amount of formaldehyde formed during the metabolism of 10 mM aminopyrene in a similar microsomal system. The rate of formaldehyde generation from tert-butanol increased to about 90 nmol/mg protein/30 minutes upon addition of azide, which inhibits catalase and thereby prevents the decomposition of hydrogen peroxide (H_2_O_2_). In other experiments in the same study, formaldehyde formation was greatly reduced when H_2_O_2_ was included but NADPH was absent or when the microsomes were boiled prior to incubation. Additionally, the rate of formaldehyde formation in the microsomal oxidizing system depended on the concentration of tert-butanol, with apparent Michaelis-Menten constants (Km) and maximum velocity values of 30 mM and 5.5 nmol/minute/mg protein, respectively. The study authors concluded that tert-butanol is metabolized to formaldehyde by a mechanism involving oxidation of NADPH, microsomal electron flow, and the generation of hydroxyl radicals (·OH) from H_2_O_2_, possibly by a Fenton-type or a Haber-Weiss iron-catalyzed reaction involving CYP450, which might serve as the iron chelate (Cederbaum and Cohen, 1980).

In a follow-up study, tert-butanol was oxidized to formaldehyde and acetone by various systems known to generate ·OH radical, including rat liver microsomes or other nonmicrosomal ·OH-generating systems (Cederbaum et al., 1983). The nonmicrosomal tests included two chemical systems: (1) the iron-catalyzed oxidation of ascorbic acid (ascorbate-Fe-EDTA [ethylenediaminetetraacetic acid]) and (2) the Fenton system of chelated ferrous iron and H_2_O_2_. In both Fenton-type systems, H_2_O_2_ served as a precursor for ·OH. Additionally, a Haber-Weiss enzymatic system involving xanthine oxidation by xanthine oxidase in the presence of Fe-EDTA was used. In this system, ·OH is thought to be produced by the interaction of H_2_O_2_ and superoxide (O_2_−). Further experiments demonstrated the involvement of ·OH in either the ascorbate-Fe-EDTA or the xanthine oxidation systems based on inhibition of formaldehyde and acetone production from tert- butanol when ·OH-scavenging agents (e.g., benzoate, mannitol) were added. Some experiments in this study of the oxidation of tert-butanol by the microsomal metabolizing system of the liver were similar to those in the previous study (Cederbaum and Cohen, 1980) except that, in addition to formaldehyde, acetone formation was measured. Again, these experiments showed the dependence of the microsomal metabolizing system on an NADPH-generating system and the ability of H_2_O_2_ to enhance, but not replace, the NADPH-generating system. Addition of chelated iron (Fe-EDTA) boosted the microsomal production of formaldehyde and acetone, while ·OH-scavenging agents inhibited their production. The study authors noted that neither Fe-EDTA nor •OH-scavenging agents are known to affect the CYP450-catalyzed oxidation of typical MFO substrates such as aminopyrene or aniline. The study also showed that known CYP450 inhibitors, such as metyrapone or SKF-525A, inhibited the production of formaldehyde from aminopyrene but not from tert-butanol. Finally, typical inducers of CYP450 and its MFO metabolizing activities, such as phenobarbital or 3-methylcholanthrene, had no effect on microsomal metabolism of tert-butanol to formaldehyde and acetone. According to the study authors, the oxidation of tert-butanol appears to be mediated by ·OH (possibly via H_2_O_2_), which can be produced by any of the tested systems by a Fenton-type reaction as follows:

H_2_ O_2_ + Fe^2 +^ - chelate → ⋅ OH + ⋅ OH^−^ + Fe^3 +^ - chelate (B-1)

According to this reaction, reduction of ferric iron (Fe^3+^) to ferrous iron (Fe^2+^) is required for continuous activity. The study authors concluded that the nature of the iron and the pathway of iron reduction within the microsomes remains unclear, even though an NADPH-dependent electron transfer or O_2_− might be involved (Cederbaum et al., 1983).

### B.1.4 Excretion

Human data on the excretion of tert-butanol derives from studies of MTBE and ETBE (Nihlén et al., 1998a, b). Eight or 10 male human volunteers were exposed to 5, 25, or 50 ppm MTBE (18.0,90.1, and 757 mg/m^3^) or ETBE (20.9,104, and 210 mg/m^3^) by inhalation during 2 hours of light exercise. The half-life of tert-butanol in urine following MTBE exposure was 8.1 ±2.0 hours (average of the 25- and 50-ppm MTBE doses); the half-life of tert-butanol in urine following ETBE exposure was 7.9 ± 2.7 hours (average of 25- and 50-ppm ETBE doses). In both studies, the urinary excretion of tert-butanol was less than 1% of the uptake or absorption of MTBE or ETBE. The renal clearance rate of tert-butanol was 0.67 ± 0.11 mL/hour-kg with MTBE exposure (average of 25- and 50-ppm MTBE doses); the renal clearance rate was 0.80 ± 0.34 mL/hour-kg with ETBE exposure (average of 25- and 50-ppm ETBE doses).

Amberg et al. (2000) exposed six volunteers (three males and three females, 28 ± 2 years old) to 18.8 and 170 mg/m^3^ ETBE. Each exposure lasted 4 hours, and the two concentrations were administered to the same volunteers 4 weeks apart. Urine was collected at 6-hour intervals for 72 hours following exposure. tert-Butanol and two metabolites of tert-butanol, HBA and MPD, also were identified in the urine. At an ETBE level of 170 mg/m^3^, tert-butanol had a half-life of 9.8 ± 1.4 hours. At the low-exposure ETBE concentration, the tert-butanol half-life was 8.2 ±2.2 hours. The predominant urinary metabolite identified was HBA, excreted in urine at 5-10 times the amount of MPD and 12-18 times the amount of tert-butanol (note: urine samples had been treated with acid before analysis to cleave conjugates). HBA in urine showed a broad maximum at 12-30 hours after exposure to both concentrations, with a slow decline thereafter. MPD in urine peaked at 12 and 18 hours after exposure to 170 and 18.8 mg/m^3^ ETBE, respectively, while tert-butanol peaked at 6 hours after exposure to both concentrations.

Amberg et al. (2000) exposed F344 NH rats to 18.8 and 170 mg/m^3^ ETBE. Urine was collected for 72 hours following exposure. Like humans, rats excreted mostly HBA in urine, followed by MPD and tert-butanol. The half-life for tert-butanol in rat urine was 4.6 ±1.4 hours at ETBE levels of 170 mg/m^3^, but half-life could not be calculated at the ETBE concentration of 18.8 mg/m^3^. Corresponding half-lives were 2.6 ± 0.5 and 4.0 ± 0.9 hours for MPD and 3.0 ± 1.0 and 4.7 ±2.6 hours for HBA. In Sprague-Dawley rats treated with radiolabeled tert-butanol by gavage at 1, 30, or 500 mg/kg, a generally constant fraction of the administered radioactivity (23-33%) was recovered in the urine at 24 hours postdosing. Only 9% of a 1,500-mg/kg administered dose was recovered in urine, however, suggesting that the urinaiy route of elimination is saturated following this dose (ARCO, 1983). Among all tested doses, most of the urinary radiolabel was attributed to a polar fraction that was not characterized, while only 0.3-5.5% of the administered dose was considered tert-butanol. The saturation in urinary elimination of radioactivity with the increased dose was considered a manifestation of saturated metabolic capacity; however, no further information was provided on the fate or balance of the administered radiolabel at any of the tested tert-butanol doses (ARCO, 1983)

Borghoff and Asgharian (1996) evaluated the disposition of ^14^C radiolabel in F344 rats and CD-1 mice after nose-only inhalation exposure to 500,1,750, or 5,000 ppm ^14^C-ETBE for 6 hours. Recovery of total radioactivity in urine, feces, and expired air was measured, and air and urine samples were analyzed for ETBE and tert-butanol. Urine samples were also analyzed for tert-butanol metabolites HBA and MPD, and ^14^CO_2_ was measured in exhaled air. Results were also obtained in rats after 13 days of exposure to 500 or 5,000 ppm ETBE. Total ETBE equivalents in exhaled air and excreted urine were found to increase linearly with exposure level, with over 90% eliminated by 48 hours (with the majority of exhalation occurring by 8 hours postexposure). Elimination shifted from being primarily in the urine at 500 ppm to occurring primarily by exhalation at 5,000 ppm in naïve rats, indicating a saturation of metabolism of ETBE to tert-butanol; this shift was greater in female rats than in males. In rats preexposed to 5,000 ppm ETBE for 13 days, most of the excretion was in urine, even at 5,000 ppm. The rats preexposed to 500 ppm ETBE also showed a shift from exhalation to urinary excretion compared with naïve rats, but to a lesser degree than that elicited by the 5,000-ppm preexposure group.

The results for the CD-1 mice were similar to those for the rats. The fraction of radiolabel in exhaled volatiles increased with exposure level while the fraction excreted in urine decreased. The exhalation pattern observed in rats showed levels of ETBE falling approximately 90% in the first 8 hours postexposure, while levels of tert-butanol exhaled rose between 0 and 3 hours postexposure and then fell more slowly between 3 and 16 hours, particularly at 5,000 ppm ETBE. The increase in tert-butanol between 0 and 3 hours postexposure can be explained by the continued metabolism of ETBE during that period. The slower decline after 3 hours likely results from a generally slower clearance of tert-butanol, which is saturated by the higher ETBE exposure levels.

### B.1.5 Physiologically Based Pharmacokinetic Models (PBPK)

Although no models of tert-butanol have been created independently of other chemicals from which it arises as a metabolite (e.g., MTBE, ETBE), submodels have been adapted specifically to estimate internal doses for administration of tert-butanol. These models are parameterized using pharmacokinetic studies with tert-butanol exposures. Three PBPK models have been developed specifically for administration of tert-butanol in rats: Leavens and Borghoff (2009), Salazar et al. (2015), and Borghoff et al. (2016): other models have incorporated tert-butanol as a submodel following MTBE administration. In Leavens and Borghoff (2009), tert-butanol is incorporated as a metabolite of MTBE and in Salazar et al. (2015) and Borghoff et al. (2016), it is incorporated as a metabolite of ETBE. In all three models, inhalation and oral exposure to tert-butanol can be simulated in rats. A detailed summary of these toxicokinetic models is provided in a separate report evaluating the pharmacokinetic (PK)/PBPK modeling of ETBE and tert-butanol (U.S. EPA, 2017).

The PBPK model described in Borghoff et al. (2016), with parameters modified as described by U.S. EPA (2017), was applied to conduct oral-to-inhalation route extrapolation based on an equivalent internal dose (the average concentration of tert-butanol in the blood). The time to reach a consistent periodic pattern of tert-butanol blood concentrations (“periodicity”), given the drinking water ingestion pattern described below, was much shorter than the duration of the oral bioassay studies. To allow for possible metabolic induction, computational scripts used a simulated time of 7 weeks, although periodicity was achieved in only a few days without metabolic induction. The average blood concentration was calculated over the last week of the simulation and was considered representative of the bioassays. To calculate steady-state values for continuous inhalation exposure, the simulations were run until the blood concentration had a <1% change between consecutive days. The continuous inhalation exposure equivalent to a given oral exposure was then selected by identifying the inhalation concentration for which the final (steady-state) blood concentration of tert-butanol matched the average concentration from water ingestion, as described above.

For simulating exposure to drinking water, the consumption was modeled as episodic, based on the drinking pattern observed in rats (Spiteri, 1982). In particular, rats were assumed to ingest water in pulses or “bouts,” which were treated as continuous ingestion, interspersed with periods of no ingestion. Eighty percent of total daily ingestion (45-minute bouts with alternating 45-minute periods of other activity) was assumed to occur during the active dark period (12 hours/day). The remaining 20% of daily ingestion was assumed to occur during the relatively inactive light period (12 hours/day), when bouts were assumed to last 30 minutes with 2.5 hours in between. This resulting pattern of drinking water ingestion is thought to be more realistic than assuming continuous 24 hours/day ingestion (see Figure B-2).

Figure B-2 Example oral ingestion pattern for rats exposed via drinking water

PBPK modeling was also used to evaluate a variety of internal dose metrics (daily average tert-butanol blood concentration, daily amount of tert-butanol metabolized in liver, daily average of ETBE blood concentration, and daily amount of ETBE metabolized in liver) to assess their correlation with different endpoints following exposure to ETBE or tert-butanol (Salazar et al., 2015). Administering ETBE either orally or via inhalation achieved similar or higher levels of tert-butanol blood concentrations or tert-butanol metabolic rates as those induced by direct tert-butanol administration (see Figure B-3). Altogether, the PBPK model-based analysis by Salazar et al. (2015) [which applied a model structurally similar to Borghoff et al. (2016)] indicates that kidney weight, urothelial hyperplasia, and chronic progressive nephropathy (CPN) yield consistent dose-response relationships using tert-butanol blood concentration as the dose metric for both ETBE and tert-butanol studies. For kidney and liver tumors, however, a consistent dose-response pattern was not obtained using any dose metric. These data are consistent with tert-butanol mediating the noncancer kidney effects following ETBE administration, but additional factors besides internal dose are necessary to explain the induction of liver and kidney tumors.

Figure B-3 Change in absolute kidney weight in female rats as a function of estimated tert-butanol blood concentration (average mg/L) and tert-butanol metabolism (average mg/h) for two structurally similar PBPK models

tert-Butanol inhalation data are from NTP (1997) (exposure for 6 hours/day, 5 days a week for 13 weeks). tert-Butanol oral data are from subchronic and chronic bioassays in NTP (1995) (ad libitum drinking water exposure for 13 weeks or 15 months). ETBE inhalation data are from two subchronic bioassays that exposed rats for 6 hours/day, 5 days/week for 13 weeks (JPEC, 2008a; Medinsky et al., 1999; Bond et al., 1996) and from one chronic bioassay that exposed rats for 6 hours/day, 5 days/week for 2 years (Saito et al., 2013; JPEC, 2010b). Oral gavage ETBE data are from bioassays that exposed rats via a single daily oral gavage for 16-26 weeks (Miyata et al., 2013; Fujii et al., 2010; JPEC, 2008b, c; Gaoua, 2004). Drinking water ETBE data are from one bioassay that exposed rats via drinking water (ad libitum) for 2 years (Suzuki et al., 2012; JPEC,2010a).

### B.1.6 Physiologically Based Pharmacokinetic (PBPK) Model Code

The PBPK acslX™ model code is available electronically through EPA’s Health and Environmental Research Online (HERO) database. All model files may be downloaded in a zipped workspace from HERO (U.S. EPA, 2016).

### B.1.7 Pharmacokinetic/Physiologically Based Pharmacokinetic (PK/PBPK) Model Evaluation

PBPK models can be used to perform route-to-route extrapolation of toxicological data. For tert-butanol, oral-to-inhalation extrapolation was performed using the concentration of tert-butanol in blood as the internal dose metric. An overview of tert-butanol toxicokinetics, as well as the scientific rationale for selecting the internal dose metric, is available in the Toxicological Review. Because the existing human PBPK model was not considered adequate (see below), default methodologies were applied to extrapolate toxicologically equivalent exposures from adult laboratory animals to adult humans. For inhalation exposures, the interspecies conversion was the ratio of animal/human blood:air partition coefficients (LA/LH), according to reference concentration (RfC) guidelines for Category 3 gases (U.S. EPA, 1994). For oral exposures, extrapolation is performed by body-weight scaling to the ¾ power (BW^3/4^) (U.S. EPA, 2011).

All available PBPK models of ETBE and its principal metabolite tert-butanol were evaluated for potential use in the assessments. A PBPK model of ETBE and its principal metabolite tert-butanol has been developed for humans exposed while performing physical work (Nihlén and Johanson, 1999). The Nihlén and Johanson model is based on measurements of blood concentrations of eight individuals exposed to 5, 25, or 50 ppm ETBE for 2 hours while physically active. This model differs from conventional PBPK models in that the tissue volumes and blood flows were calculated from individual data on body weight and height. Additionally, to account for physical activity, blood flows to tissues were expressed as a function of the workload. These differences from typical PBPK models preclude allometric scaling of this model to other species for cross-species extrapolation. Because there are no oral exposure toxicokinetic data in humans, this model does not have a mechanism for simulating oral exposures, which prevents using the model in animal-to-human extrapolation for that route.

A number of PBPK models were developed previously for ETBE’s related compound, methyl tertiary butyl ether (MTBE) and the metabolite tert-butanol that is common to both parent compounds (Borghoff et al., 2010; Leavens and Borghoff, 2009; Blancato et al., 2007; Kim et al., 2007; Rao and Ginsberg, 1997; Borghoff et al., 1996). EPA (Salazar et al., 2015) developed a PBPK model for ETBE and tert-butanol in rats by integrating information from across these earlier models. Another model for ETBE and tert-butanol was published by Borghoff et al. (2016), adapted with modest structural differences from the Leavens and Borghoff (2009) MTBE/tert-butanol model. Brief descriptions below highlight the similarities and differences between the MTBE/tert-butanol models of Blancato et al. (2007) and Leavens and Borghoff (2009), and the ETBE/tert-butanol models of Salazar et al. (2015) and Borghoff et al. (2016).

#### The models of Blancato et al. (2007) and Leavens and Borghoff (2009)

The Blancato et al. (2007) model is an update of the earlier Rao and Ginsberg (1997) model, and the Leavens and Borghoff (2009) model is an update of the Borghoff et al. (1996) model. Both the Blancato et al. (2007) and Leavens and Borghoff (2009) models are flow-limited models that predict amounts and concentrations of MTBE and its metabolite tert-butanol in blood and six tissue compartments: liver, kidney, fat, brain, and rapidly and slowly perfused tissues. These tissue compartments are linked through blood flow, following an anatomically accurate, typical, physiologically based description (Andersen, 1991). The parent (MTBE) and metabolite (tert-butanol) models are linked by the metabolism of MTBE to tert-butanol in the liver. Oral and inhalation routes of exposure are included in the models for MTBE; Leavens and Borghoff (2009) also included oral and inhalation exposure to tert-butanol. Oral doses are assumed 100% bioavailable and 100% absorbed from the gastrointestinal tract, represented with a first-order rate constant. After inhalation, MTBE or tert-butanol is assumed to enter the systemic blood supply directly, and the respiratory tract is assumed to be at pseudo-steady state. Metabolism of MTBE by CYP450s to formaldehyde and tert-butanol in the liver is described with two Michaelis-Menten equations representing high- and low-affinity enzymes. tert-Butanol is conjugated either with glucuronide or sulfate, or further metabolized to acetone through 2-methyl-1,2-propanediol (MPD) and hydroxyisobutyric acid (HBA); the total metabolic clearance of tert-butanol by both processes is described by a single Michaelis-Menten equation in the models. All model assumptions are considered valid for MTBE and tert-butanol.

In addition to differences in fixed parameter values between the two models and the addition of exposure routes for tert-butanol, the Leavens and Borghoff (2009) model has three features not included in the Blancato et al. (2007) model: (1) the alveolar ventilation was reduced during exposure, (2) the rate of tert-butanol metabolism increased over time to account for induction of CYP enzymes, and (3) binding of MTBE and tert-butanol to alpha 2u-globulin was simulated in the kidney of male rats. The Blancato et al. (2007) model was configured through EPA’s PBPK modeling framework, Exposure-Related Dose Estimating Model, which includes explicit pulmonary compartments. The modeling assumptions related to alveolar ventilation, explicit pulmonary compartments, and induction of metabolism of tert-butanol are discussed in the model evaluation section below.

MTBE and tert-butanol binding to alpha 2u-globulin in the kidneys of male rats were incorporated in the PBPK model of MTBE by Leavens and Borghoff (2009). Binding to alpha 2u-globulin is one hypothesized mode of action (MOA) for the observed kidney effects in MTBE-exposed animals. For a detailed description of the role of alpha 2u-globulin and other modes of action for kidney effects, see the kidney mode-of-action section of the Toxicological Review (Section 1.2.1). In the Leavens and Borghoff (2009) model, binding of MTBE to alpha 2u-globulin was applied to describe sex differences in kidney concentrations of MTBE and tert-butanol, but acceptable estimates of MTBE and tert-butanol pharmacokinetics in the blood are predicted in other models that did not consider alpha 2u-globulin binding. Moreover, as discussed below, EPA’s implementation of the Leavens and Borghoff (2009) model did not adequately fit the available tert-butanol i.v. dosing data, adding uncertainty to the parameters they estimated.

The Blancato et al. (2007) and Leavens and Borghoff (2009) PBPK models for MTBE were specifically evaluated by comparing predictions from the tert-butanol portions of the models with the tert-butanol i.v. data of Poet et al. (1997) (see Figure B-4). Neither model adequately represented the tert-butanol blood concentrations. Modifications of model assumptions for alveolar ventilation, explicit pulmonary compartments, and induction of metabolism of tert-butanol did not significantly improve model fits to the data.

Figure B-4 Comparison of the tert-butanol portions of existing MTBE models with tert-butanol blood concentrations from i.v. exposure by Poet et al. (1997)

Neither the (A) Blancato et al. (2007) nor the (B) Leavens and Borghoff (2009) model adequately represents the measured tert-butanol blood concentrations.

#### The model of Salazar et al. (2015)

To better account for the tert-butanol blood concentrations after i.v. tert-butanol exposure, the model by Leavens and Borghoff (2009) was modified by adding a pathway for reversible sequestration of tert-butanol in the blood (Salazar et al., 2015). Sequestration of tert-butanol was modeled using an additional blood compartment, which tert-butanol can enter reversibly, represented by a differential mass balance (see Figure B-5). Other differences in model structure are that the brain was included in the other richly perfused tissues compartment and binding to alpha 2u-globulin was not included. Binding to alpha 2u-globulin was neglected because it was assumed to not significantly affect the blood concentration or metabolic rate of ETBE or tert-butanol, the two dose metrics being used for route-to-route extrapolation. This model improved the fit to tert-butanol blood concentrations after tert-butanol i.v. exposures [see Salazar et al. (2015)]. Additionally, the model adequately estimated the tert-butanol blood concentrations after inhalation and oral gavage exposures. The ETBE submodel was based on the MTBE component of the Leavens and Borghoff (2009) model. The model assumed two pathways for metabolism of ETBE to tert-butanol, and the metabolic parameters were optimized to fit toxicokinetic data. Partition coefficients of ETBE were based on data of Nihlén and Johanson (1999).

Figure B-5 Schematic of the Salazar et al. (2015) PBPK model for ETBE and its major metabolite tert-butanol in rats

Exposure can be via multiple routes including inhalation, oral, or i.v. dosing. Metabolism of ETBE and tert-butanol occurs in the liver and is described by Michaelis-Menten equations with two pathways for ETBE and one for tert-butanol. ETBE and tert-butanol are cleared via exhalation, and tert-butanol is additionally cleared via urinary excretion.

#### The model of Borghoff et al. (2016)

The Borghoff et al. (2016) models for ETBE and tert-butanol were based on Leavens and Borghoff (2009), including binding of ETBE and tert-butanol to alpha 2u-globulin and induction of tert-butanol metabolism, but with some structural changes. The revised model lumped gastrointestinal tract tissue and brain tissue into the richly perfused compartment [Leavens and Borghoff (2009) modeled these compartments separately]. Borghoff et al. (2016) assumed that urinary clearance was a function of central venous blood concentration and effectively occurs from that compartment, as opposed to clearance from the kidney venous blood assumed by Leavens and Borghoff (2009). Using the new structure, urinary clearance was reparameterized to fit the intravenous data by Poet et al. (1997). The model assumed a single oxidative metabolic pathway for metabolism of ETBE to tert-butanol using parameters from Rao and Ginsberg (1997), instead of the two-pathway models assumed by Leavens and Borghoff (2009) (for MTBE) and Salazar et al. (2015). The model did not incorporate the tert-butanol blood sequestration kinetics included in the tert-butanol model. It did, however, incorporate the oral absorption rate of tert-butanol estimated by Salazar et al. (2015). Partition coefficients for ETBE were obtained from Kaneko et al. (2000). Rate constants for binding of ETBE to alpha 2u-globulin and its dissociation were assumed to be the same as estimated for MTBE by Leavens and Borghoff (2009). Finally, unlike the Leavens and Borghoff (2009) model, the Borghoff et al. (2016) model assumed a lower-bound alveolar ventilation for all times and exposures, not just during periods of inhalation exposure.

To simulate induction of tert-butanol metabolism, the default metabolic rate of tert-butanol clearance is multiplied by an exponential function of the form [1 + A(1 - e^-kt^)], where A is the maximum fold increase above baseline metabolism, k is the rate constant for the ascent to maximum induction, and t is time. Because metabolic induction does not occur instantaneously, but involves a delay for induction of ribonucleic acid transcription and translation, Borghoff et al. (2016) assumed that induction did not begin until 24 hours after the beginning of exposure. But the computational implementation then treated the effect as if the enzyme activity suddenly jumped each 24 hours to the level indicated by the time-dependent equation shown in the paper. This stepwise increase in activity was not considered realistic. Therefore, in evaluating the effect of induction, EPA treated the induction as occurring continuously with time but beginning at 12 hours after the start of exposure. This change would not affect long-term steady-state or periodic simulations, in particular those used to characterize bioassay conditions. But it does have a modest effect on simulations between 12 hours and 24 hours, which are compared with experimental data below for the purpose of model validation. However, with further review of the existing data on liver histology (which would also reflect metabolic induction if it occurs, as detailed below), EPA determined that histological changes are likely to occur only at the very highest exposure levels and hence not at levels where the model is applied for route-to-route extrapolation. Therefore, the maximal induction was set to zero unless otherwise noted.

The form of the equations for hepatic metabolism in the Borghoff et al. (2016) model was revised to be a function of the free liver concentration (CL), specifically the concentration in the venous blood leaving the liver (CVL), rather than the concentration in the liver tissue (see Figure B-6). In order to maintain the integrity of all prior model simulations and parameter estimations, EPA updated the Km’s for ETBE and tert-butanol by scaling them by the liver:blood partition coefficients. As a result, the model produces identical results as before without re-estimating a fitted parameter.

Finally, a discrepancy between the pulmonary ventilation value as described by Borghoff et al. (2016), in particular as the lower limit of values reported by Brown et al. (1997), should be noted. Borghoff et al. (2016) claim that an allometric coefficient of 18.9 L/hour/kg^3/4^ (allometric coefficient provided here reflects actual use in model code) is the lower limit. For a 0.25 kg rat, this value yields an absolute ventilation rate of 6.6822 L/hour or 111.3 mL/minute. In Table 31 of Brown et al. (1997), the mean and range of values given for the rat are 52.9 and 31.5-137.6 mL/minute/100 g BW]. From the text immediately following this table, it is clear that the mean and range are not scaled to BW^3/4^, but exactly as indicated. Hence, for a 250 g rat, they correspond to 132.25 and 78.75-344 mL/minute. Use of 18.9 L/hour/kg^3/4^corresponds to a ventilation rate 61% of the way between the lower limit and the mean for a 0.25 kg rat. It can be noted that 31.5 mL/minute/100 g BW, the actual lower limit, equals 18.9 L/hour/kg^1.0^ (i.e., the respiration per kg BW, not per kg BW^3/4^). Thus, the discrepancy appears due to a mistaken translation in allometric scaling.

The fact that Borghoff et al. (2016) and Leavens and Borghoff (2009) used a ventilation rate closer to the mean than the lower limit may explain why it was also necessary to incorporate a fraction of tert-butanol available for alveolar absorption of 0.6. When considering the plots of model simulations versus data below, it seems that model fits to the data would be improved by further decreasing ventilation, which could now be justified. But EPA has chosen to keep the value of alveolar ventilation (Q_pc_) and absorption fraction as published by Borghoff et al. (2016).

Figure B-6 Schematic of the Borghoff et al.(2016) PBPK model for ETBE and its major metabolite tert-butanol in rats

Table B-1 PBPK model physiologic parameters and partition coefficients^*^

Body weight and organ volumes as fraction of body weight
Body weight (kg) | 0.25 | Brown et al. (1997)
Liver | 0.037 | Brown et al. (1997)
Kidney | 0.0073 | Brown et al. (1997)
Fat | 0.35 × BW + 0.00205 | Brown et al. (1997)
Richly perfused (total) | 0.136 | Brown et al. (1997)
Richly perfused | 0.0177 | ^a^
Poorly perfused (total) | 0.757 | Brown et al. (1997)
Poorly perfused | 0.75495 − 0.35 × BW
Blood | 0.074 | Brown et al. (1997)
Rest of body (not perfused) | 0.107 | Brown et al. (1997)
Cardiac output and organ blood flows as fraction of cardiac output
Cardiac output (L/h-kg) | 18.9 | Brown et al. (1997) ^b^
Alveolar ventilation (L/h-kg) | 18.9 | Brown et al. (1997) ^b^
Liver | 0.174 | Brown et al. (1997) ^c^
Kidney | 0.141 | Brown et al. (1997)
Fat | 0.07 | Brown et al. (1997)
Richly perfused (total) | 0.47 | ^d^
Richly perfused | 0.155 | ^e^
Poorly perfused (total) | 0.53 | Brown et al. (1997)
Poorly perfused | 0.46 | ^f^
Partition coefficients for ETBE
Blood:air | 11.6 | Kaneko et al. (2000)
Liver:blood | 2.9 | Kaneko et al. (2000)
Fat:blood | 11.7 | Kaneko et al. (2000)
Richly perfused:blood | 2.9 | Kaneko et al. (2000)
Poorly perfused:blood | 1.9 | ^g^
Kidney:blood | 2.9 | ^h^
Partition coefficients for tert-butanol
Blood:air | 481 | Borghoff et al. (1996)
Liver:blood | 0.83 | Borghoff et al. (1996)
Fat:blood | 0.4 | Borghoff et al. (1996)
Richly perfused:blood | 0.83 | Borghoff et al. (1996)
Poorly perfused:blood | 1.0 | Borghoff et al. (1996)
Kidney:blood | 0.83 | Borghoff et al. (2001)

* Values have been updated to incorporate corrections from a quality assurance (QA) review and to include values to the number of digits used in the model code.

a 0.165—Σ(kidney,liver.blood).

b Lower limit of alveolar ventilation for rat reported in Brown et al. (1997); alveolar ventilation is set equal to cardiac output.

c Sum of liver and gastrointestinal blood flows.

d Brown et al. (1997) only accounts for 94% of the blood flow. This assumes unaccounted 6% is richly perfused.

e 0.47—Σ(kidney, liver).

f 0.53-fat.

g Set equal to muscle tissue (Borghoff et al., 2016).

h Set equal to richly perfused tissue (Borghoff et al., 2016).

Table B-2 PBPK model rate constants

Parameter | Value | Source or reference
tert-butanol rate constants
TBA first-order absorption constant (1/h) | 5.0 | Salazar et al. (2015)
Fraction of TBA absorbed in alveolar region | 0.6 | Medinsky et al. (1993)
Urinary clearance of TBA (L/h/kg^0.75^) | 0.015 | Borghoff et al. (2016)
Scaled maximum metabolic rate of TBA (μmol/h/kg) | 54 | Borghoff et al. (1996), Rao and Ginsberg (1997)
Michaelis-Menten constant (μmol/L) | 457^a^ | Borghoff et al. (1996), Rao and Ginsberg (1997)
Maximum percentage increase in metabolic rate | 0.0 | 124.9 used by Leavens and Borghoff (2009)
Rate constant for ascent to maximum (1/d)^b^ | 0.3977 | Leavens and Borghoff (2009)
ETBE rate constants
ETBE first-order absorption constant (1/h) | 1.6 | Leavens and Borghoff (2009)
Scaled maximum metabolic rate of ETBE (μmol/h/kg^0.75^) | 499 | Rao and Ginsberg (1997)
Michaelis-Menten constant for ETBE (μmol/L) | 430^a^ | Rao and Ginsberg (1997)
alpha 2u-globulin binding parameters
Steady-state free kidney alpha 2u-globulin (μmol/L) | 550^c^ | Leavens and Borghoff (2009)
First-order constant for hydrolysis of free alpha 2u-globulin (1/h) | 0.31 | Leavens and Borghoff (2009)
First-order constant for hydrolysis of bound alpha 2u-globulin (1/h) | 0.11 | Leavens and Borghoff (2009)
Second-order binding constant for TBA to alpha 2u-globulin (L/μmol/h) | 1.3 | Leavens and Borghoff (2009)
Alpha 2u-globulin dissociation constant for TBA (μmol/L) | 120 | Leavens and Borghoff (2009)
First-order constant for unbinding of TBA from alpha 2u-globulin (1/h) | Calculated^d^
Second-order binding constant for ETBE to alpha 2u-globulin (L/μmol/h) | 0.15 | Leavens and Borghoff (2009)
Alpha 2u-globulin dissociation constant for ETBE (μmol/L) | 1 | Leavens and Borghoff (2009)
First order constant for unbinding of ETBE from alpha 2u-globulin (1/h) | Calculated^e^

a Based on dividing the original values in Borghoff et al. (1996) and Rao and Ginsberg (1997) [used by Borghoff et al. (2016)] by the corresponding liver partition coefficients: 379/0.83 = 457 for tert-butanol kinetics, and 1,248/2.9 = 430 for ETBE kinetic pathway 1.

b Note: Model revised from a daily stepwise induction change to a continuous change (with a 12-h time lag), while still maintaining the default parameters.

c Based on values ranging from ~160 to 1,000 μmol/L (Carruthers et al., 1987; Charbonneau et al., 1987; Olson et al., 1987; Stonard et al., 1986).

d Product of alpha 2u-globulin dissociation constant for tert-butanol and second-order binding constant for tert-butanol to alpha 2u-globulin.

e Product of alpha 2u-globulin dissociation constant for ETBE and second-order binding constant for ETBE to alpha 2u-globulin.

### B.1.8 Toxicokinetic Data Extraction and Selected Model Outputs

#### Data extraction and adjustments

The ARCO (1983) study reported tert-butanol blood levels after oral gavage exposure primarily as tert-butanol equivalents based on total ^14^C activity, which does not distinguish between tert-butanol and its metabolites. However, for oral doses of 1 and 500 mg/kg, the fractions of activity identifiable as tert-butanol were also reported, although not at identical time points. Therefore, empirical bi-exponential curves (see Figure B-7) were used to interpolate between the time points when total tert-butanol equivalents were measured to estimate total equivalents at other times. The total equivalents calculated this way were then multiplied by the fraction of tert-butanol reported at 0.5, 3, 6, and 12 hours for 1 mg/kg (ARCO (1983), see Table 24) and 500 mg/kg (ARCO (1983), see Table 25) to obtain the data used for PBPK modeling (see Table B-4).

Figure B-7 tert-Butanol PK data for 1 and 500 mg/kg oral exposures from ARCO (1983)

Time-course data and empirical regressions for tert-butanol equivalents in rats following oral exposure to 1 or 500 mg/kg ^14^C-TBA (ARCO, 1983). For 1 mg/kg, the single exponential regression reported by ARCO (1983) was 1.73*exp(−0.0946*t; dashed line), but it did not appear to adequately fit the data. A bi-exponential regression (solid line) was found by minimizing the sum of square errors between the regression and data in Excel: 0.4874*exp(−0.7055*t) + 1.404*exp(−0.06983*t). For 500 mg/kg the bi-exponential regression reported by ARCO (1983) appeared sufficient: 554*exp(−0.0748*t) − 426*exp(−3.51*t).

The single-dose data from JPEC (2008a) were taken from Appendix Table 12 of that report. The values for the P-5 component were converted from ETBE equivalents to mg/L tert-butanol. For example, at 5 mg/kg-day, 416 ng ETBE-eq/mL is reported for P-5 in animal #17. The corresponding concentration in mg/L for tert-butanol is then calculated as (416 ng ETBE-eq/mL) × (1,000 mL/L) × (10^−6^ mg/ng) × (74.12 [molecular weight (MW] tert-butanol])/(102.17 [MW ETBE]) = 0.302 mg tert-butanol-eq/L. Likewise, the data for the repeated-dose study (JPEC, 2008d), Days 7 and 14, were converted from the P-5 values in Appendix Table 7, p. 53 of that report. (The data from the single-dose study were combined with the Days 7 and 14 data from the multiple-dose study for comparison with model simulations of 14-day dosing.)

The (JPEC, 2008a) studies measured tert-butanol in plasma only, unlike the Poet et al. (1997) and Leavens and Borghoff (2009) studies, which measured tert-butanol in whole blood. Based on the measurements of plasma and whole blood by (JPEC, 2008a), the concentration of tert-butanol in plasma is approximately 130% of the concentration in whole blood (see Table B-5). The tert-butanol plasma concentrations measured by Japan Petroleum Energy Center (JPEC) were therefore divided by 1.3 to obtain the expected concentration in whole blood for comparison with the PBPK model.

Table B-3 Summary of pharmacokinetic data used for model calibration and evaluation

Exposure | | Measured | | Data source | Figure Number in Salazar et al. (2015) | Conversion | Notes
Chemical | Route | Chemical | Medium | Data source | Figure Number in Salazar et al. (2015) | Conversion | Notes
TBA | i.v. | TBA | Blood | Poet et al. (1997) Figures 1 and 2 | 3A | μM to mg/L | Digitized from the figure
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8A-B | 3B | μM to mg/L | Digitized from the figure showing only 1 d of exposure
TBA | Gavage | TBA | Blood | ARCO (1983), percentage total TBA, Tables 24−25; TBA equivalents, Figure 6 | 3C | TBA equivalents to TBA concentration
ETBE | Gavage | TBA | Blood | JPEC (2008a) Appendix 12 | 4A | ETBE equivalents to mg/L TBA | “P5” is TBA
ETBE | Gavage | TBA | Urine | JPEC (2008a) Appendix 13 | 4B | ETBE equivalents to mg/L TBA | “P5” is TBA
ETBE | Inhalation | ETBE | Blood | Amberg et al. (2000) Table 5 | 4C | μM to mg/L
ETBE | Inhalation | TBA | Blood | Amberg et al. (2000) Table 5 | 4D | μM to mg/L
ETBE | Inhalation | TBA | Urine | Amberg et al. (2000) Table 6 and Figure 4 | 4E | μM to mg/L
ETBE | Inhalation | ETBE | Exhaled air | Borghoff et al. (1996) | 4F | μmoles to mg | Cumulative mass
ETBE | Inhalation | TBA | Exhaled air | Borghoff et al. (1996) | 4G | μmoles to mg | Cumulative mass
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8B | 5A–B | μM to mg/L | Digitized from the figure
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8A | 5C–D | μM to mg/L | Digitized from the figure
ETBE | Gavage | TBA | Blood | JPEC (2008a) Appendix 12 | 5E | ETBE equivalents to mg/L TBA | “P5” is TBA

Table B-4 Conversion of ARCO (1983) total tert-butanol equivalents and serum fraction data to tert-butanol concentrations

Time (h) | % TBA^a^ | Total TBA equivalents interpolated (μg/mL)^b^ | TBA concentration using interpolated equivalents (μg/mL = mg/L)^c^ | Total TBA equivalents measured at nearest time-point (time measured; h)^d^ | TBA concentration using nearest time-point (mg/L)^e^
1 mg/kg data
0.5 | 57.3 | 1.6982 | 0.9731 | 1.69 (0.5) | 0.9684
3 | 25 | 1.1972 | 0.2993 | 1.26 (2.67) | 0.3150
6 | 18.1 | 0.9304 | 0.1684 | 0.97 (5.33) | 0.1756
12 | 1 | 0.6074 | 0.006074 | 0.68 (10.67) | 0.006800
500 mg/kg data
0.5 | 22.9 | 460.0 | 105.34 | 445 (0.5) | 101.91
3 | 20.4 | 442.6 | 90.30 | 438 (2.67) | 89.35
6 | 18.7 | 353.7 | 66.14 | 393 (5.33) | 73.49
12 | 18.5 | 225.8 | 41.77 | 269 (10.67) | 49.77

a From Table 24, p. 48 of ARCO (1983) (1 mg/kg) and Table 25, p. 49 of ARCO (1983) (500 mg/kg).

b Using bi-exponential functions given in the legend of Figure B-7.

c Values used in PBPK modeling; %TBA × total TBA equivalents interpolated.

d From Table 14, p. 32 of ARCO (1983) (1 mg/kg) and Table 11, p. 27 of ARCO (1983) (500 mg/kg).

e %TBA × total TBA equivalents at nearest time-point.

Table B-5 Ratio of ^14^C activity in blood versus plasma after ^14^C-ETBE exposures in rats (JPEC, 2008a)

Time (h) | Animal number | Plasma (ng ^14^C-eq/mL) | Blood (ng ^14^C-eq/mL) | Plasma/blood (%)
Single dose, JPEC (2008a) Appendix Table 5, p. 94
8 | 97 | 78,133 | 40,667 | 192.1
8 | 98 | 95,533 | 80,000 | 119.4
8 | 99 | 89,367 | 64,667 | 138.2
8 | 100 | 72,400 | 62,333 | 116.2
24 | 37 | 10,900 | 8,800 | 123.9
24 | 38 | 19,133 | 14,433 | 132.6
24 | 39 | 19,433 | 15,400 | 126.2
24 | 40 | 30,767 | 22,967 | 134.0
72 | 41 | 2,133 | 1,600 | 133.3
72 | 42 | 2,833 | 3,033 | 93.4
72 | 43 | 4,033 | 3,200 | 126.0
72 | 44 | 3,167 | 2,333 | 135.7
| | | Mean ± SD | 130.9 ± 22.8
Single dose, JPEC (2008a) Appendix Table 3, p. 91
8 | 17 | 2,853 | 1,784 | 159.9
8 | 18 | 2,850 | 1,802 | 158.2
8 | 19 | 2,629 | 1,568 | 167.7
8 | 20 | 3,918 | 2,718 | 144.2
24 | 21 | 1,692 | 1,255 | 134.8
24 | 22 | 846.7 | 642.9 | 131.7
24 | 23 | 1,048 | 785 | 133.5
24 | 24 | 761.7 | 591.3 | 128.8
72 | 25 | 49.6 | 40 | 124.0
72 | 26 | 34.2 | 29.2 | 117.1
72 | 27 | 79.2 | 60.8 | 130.3
72 | 28 | 107.9 | 84.6 | 127.5
168 | 29 | 12.9 | 13.3 | 97.0
168 | 30 | 17.5 | 13.8 | 126.8
168 | 31 | 26.7 | 24.2 | 110.3
168 | 32 | 40 | 35.8 | 111.7
| | | Mean ± SD | 131.5 ± 18.9
Repeated dose, JPEC (2008a), Appendix Table 3, p. 49
8 (7 d dosing) | | 3,789 | 3,029 | 125.1
8 (7 d dosing) | | 5,041 | 3,988 | 126.4
8 (7 d dosing) | | 4,914 | 3,938 | 124.8
8 (7 d dosing) | | 5,608 | 4,638 | 120.9
24 (7 d dosing) | | 2,740 | 1,908 | 143.6
24 (7 d dosing) | | 3,433 | 2,575 | 133.3
24 (7 d dosing) | | 2,488 | 1,888 | 131.8
24 (7 d dosing) | | 963.3 | 812.5 | 118.6
8 (14 d dosing) | | 5,665 | 4,546 | 124.6
8 (14 d dosing) | | 5,175 | 4,075 | 127.0
8 (14 d dosing) | | 3,889 | 3,058 | 127.2
8 (14 d dosing) | | 5,090 | 3,858 | 131.9
24 (14 d dosing) | | 2,003 | 1,508 | 132.8
24 (14 d dosing) | | 2,121 | 1,692 | 125.4
24 (14 d dosing) | | 1,948 | 1,354 | 143.9
24 (14 d dosing) | | 1,037 | 804.2 | 128.9
72 (14-d dosing) | | 1,378 | 1,138 | 121.1
72 (14-d dosing) | | 301.3 | 245.8 | 122.6
72 (14-d dosing) | | 110 | N.D.
72 (14-d dosing) | | 421.3 | 337.5 | 124.8
| | | Mean ± SD | 128.1 ± 6.85

N.D. = not detected; SD = standard deviation.

#### Selected model comparisons applying the Borghoff et al. (2016) model

The modeling code was obtained by the authors of Borghoff et al. (2016). The modeling language and platforms is acslX (Advanced Continuous Simulation Language, Aegis, Inc., Huntsville, Alabama).

The following modifications were made:

1) The periodic drinking water pathway was incorporated into the continuous simulation language (CSL) file, and the continuous oral dose rate function was modified slightly to improve flexibility of the model.
2) For simulations showing the effect of including enzyme induction, the code was modified slightly in the CSL file to improve continuity. Daily step functions in metabolic chances were replaced with a continuous function but delayed by 12 hours.
3) Otherwise enzyme induction was not used (set to zero).
4) In the PBPK model code, the changes to the Michaelis-Menten constants described as footnotes in Table B-2 above were not made in the PBPK parameter script (MTBEparam.m). Instead, parameters were redefined in the core model *CSL file as scaling calculations in the parameters section of the INITIAL bloc:
  a. Km1vetbe = Km1etbe/Pletbe
  b. Km2vetbe = Km2etbe/Pletbe
  c. Kmvtba = Kmtba/Pltba
5) Tissue volumes and the rate of hydrolysis of free alpha 2u-globulin were corrected (slightly) to values shown in Table B-1.
6) All model scripts previously used to evaluate model fits of the Salazar et al. (2015) model were adapted to run the Borghoff et al. (2016) model. Model parameters were set to uniform values for all simulations highlighted in this section, unless otherwise noted.
7) Digitized data from Amberg et al. (2000) were updated subsequent to a quality assurance (QA) review.
8) Tabulated data from Borghoff and Asgharian (1996) were updated subsequent to a QA review.

The PBPK acslX model code is available electronically through EPA’s HERO database. All model files may be downloaded in a zipped workspace from HERO (U.S. EPA, 2016). The model contains workspaces for the EPA implementation of the Salazar et al. (2015) model, the unchanged version of the Borghoff et al. (2016) model, and the EPA implementation of the Borghoff et al. (2016) model.

Selected model outputs compared with the experimental data sets are provided in Figure B-8.

Figure B-8 Comparison of the Borghoff et al. (2016) model predictions with measured tert-butanol blood concentrations for i.v., inhalation, and gavage exposure to tert-butanol

Source: (A) i.v. data from Poet et al. (1997); (B) inhalation data from Leavens and Borghoff (2009); and (C) gavage data from ARCO (1983).

The model results for the i.v. data are significantly improved from the Blancato et al. (2007) and Leavens and Borghoff (2009) model results presented previously. As evident here and in the Borghoff et al. (2016) study, the Borghoff et al. (2016) model generally over-predicts tert-butanol blood and urine concentrations (see Figure B-9). Some attempts were made to improve model fit in the EPA model implementation (such as adjusting inhalation, urinary, and induction parameter values); however, the default values were maintained in the final model.

Figure B-9 Comparison of Borghoff et al. (2016) model predictions with measured amounts of tert-butanol after gavage of ETBE

The data points show the measurements from the four individual rats in the JPEC (2008a) study. The concentrations of tert-butanol in blood are shown in (A). The amount of tert-butanol in urine is shown in (B). Note that the over-prediction of tert-butanol in urine (B) is by a factor 3- to 10-fold.

The predictions of the model are compared with amounts measured by Amberg et al. (2000) after ETBE inhalation in Figure B-10. The prediction of the tert-butanol blood concentrations are slightly higher than was measured. The tert-butanol blood concentration would be reduced if exposed animals were reducing their breathing rate or other breathing parameters, but the exposure concentration of ETBE exposure is unlikely to be high enough to cause a change in breathing parameters because, at the much higher ETBE concentration in the ARCO (1983) study (5,000 ppm), changes in breathing were not noted; the model already uses a lower-bound estimate of respiration rate and cardiac output for all simulations, and the model predictions fit most measured concentrations well. However, the urinary elimination of tert-butanol is significantly overestimated (~ 3- to 10-fold) by the tert-butanol submodel (see Figure B-11).

Figure B-10 Comparison of Borghoff et al. (2016) model predictions with measured amounts after a 4-hour inhalation exposure to 4 and 40 ppm ETBE

Concentrations in blood are shown in (A) for ETBE, (B) for tert-butanol. The amount of tert-butanol in urine is shown in (C) for the 40 ppm exposure. The data are from Amberg et al. (2000).

Figure B-11 Comparison of Borghoff et al. (2016) model predictions with measured amounts of ETBE and tert-butanol in exhaled breath after a 6-hour inhalation exposure to 500, 1,750, and 5,000 ppm ETBE

The data points are from the Borghoff and Asgharian (1996) study. The model significantly over-predicted exhaled breath of both ETBE and tert-butanol following ETBE inhalation exposure for male rats and the exhaled tert-butanol for female rats. The model currently assumes that 100% of inhaled ETBE, but only 60% of inhaled tert-butanol, is available for alveolar absorption. The inhalation availability may have a significant impact on estimated exhaled breath amounts but was not adjusted to fit this data set.

Figure B-12 Comparison of the Borghoff et al. (2016) model predictions with measured amounts of tert-butanol in blood after repeated inhalation exposure to tert-butanol

Male rats were exposed to 239,444, or 1,726 ppm and female rats were exposed to 256,444, or 1,914 ppm tert-butanol for up to 8 consecutive days (Borghoff et al., 2001). tert-Butanol blood concentrations are better predicted by the model after 8 days of exposure with enzyme induction (right panels) compared to those without enzyme induction (left panels).

The increased tert-butanol metabolism better estimates the measured tert-butanol blood concentrations as shown in a comparison of the model predictions and experimental measurements in Figure B-12. The male rats have lower tert-butanol blood concentrations after repeated exposures than female rats, and this difference could indicate greater induction of tert-butanol metabolism in males or other physiologic changes, such as in ventilation or urinary excretion (see Figure B-13).

Figure B-13 Comparison of EPA model predictions with measured amounts of tert-butanol in blood after 5 mg/kg-day ETBE gavage for up to 14 days in male rats

The data show the individual measurements of the four rats in the JPEC (2008a) study. Adding enzyme induction to the model has a small effect on the predicted tert-butanol blood concentrations, and the model predictions are closer to measured data when induction is not included.

## B.2 OTHER PERTINENT TOXICITY INFORMATION

### B.2.1 Other Toxicological Effects

#### Synthesis of Other Effects

Effects other than those related to kidney, thyroid, reproduction, development, and neurodevelopment were observed in some of the available rodent studies. These indude liver and urinary bladder effects. As previously mentioned in the Study Selection section of the Toxicological Review, all studies discussed employed inhalation, gavage, or drinking water exposures for ≥30 days. Studies are arranged in evidence tables by effect, species, duration, and design. The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment.

Central nervous system effects similar to those of ethanol (i.e., animals appearing intoxicated and having withdrawal symptoms after cessation of oral or inhalation exposure) were observed with tert-butanol. Severity of central nervous system symptoms increased with dose and duration of exposure. Study quality and utility concerns associated with these studies [e.g., inappropriate exposure durations, lack of data reporting, small number of animals per treatme nt group; Grant and Samson (1981); Snell and Harris (1980); Thurman et al. (1980); McComb and Goldstein (1979a, 1979b); wood and Laverty (1979)] preclude an understanding of potential neurotoxicity following tert-butanol exposure; therefore, central nervous system studies are not discussed further.

Exposure-response arrays of liver and urinary bladder effects are provided in Figure B-14 and Figure B-15 for oral and inhalation studies, respectively.

##### Kidney effects

Absolute and relative kidney-weight numerical data are presented in Table B-6.

##### Liver effects

Liver weight and body weight were demonstrated to be proportional, and liver weight normalized to body weight was determined to be optimal for data analysis (Bailey et al., 2004); thus, only relative liver weight is presented and considered in the determination of hazard. Although some rodent studies observed liver effects (organ weight changes and histopathologic lesions), the effects were not consistent across the evidence base. Increases in relative liver weight with tert-butanol exposure were observed, but the results pertaining to histopathologic changes were inconsistent (see Table B-7 and Table B-8). The NTP (1995) oral subchronic and chronic studies did not observe treatment-related effects on liver histopathology in either sex of F344 rats. In a 10-week study in Wistar rats, several liver lesions (including necrosis) and increased liver glycogen were observed in male rats (no females were included in the study) at 575 mg/kg-day, the only dose used (Acharva et al., 1997; Acharva et al., 1995). The study provided no incidence or severity data. The dose used in this rat study was in the range of the lower doses used in the NTP (1995) subchronic rat study. An increased incidence of fatty liver was observed in the male mice of the highest dose group in the 2-year mouse bioassay, but no histopathologic changes were seen in the subchronic mouse study (NTP, 1995). No treatment-related effects in liver histopathology were observed in rats or mice in the NTP (1997) sub chronic inhalation study.

##### Urinary bladder effects

Subchronic studies reported effects in the urinary bladder (see Table B-9), although the chronic studies indicated little progression in incidence with increased exposure. Transitional epithelial hyperplasia of the urinary bladder was observed in male rats and male mice after 13 weeks of exposure at doses of 3,610 mg/kg-day (male rats) and ≥3,940 mg/kg-day (male mice). In rats, the increase in transitional epithelial hyperplasia of the urinary bladder was not observed in the 2-year study. Male mice exposed at the high dose (2,070 mg/kg-day) for 2 years exhibited minimal transitional epithelial hyperplasia of the urinary bladder. Neither female rats nor female mice showed increased incidences of this lesion. Both sexes of mice demonstrated incidences of minimal to mild inflammation in the urinary bladder after both subchronic and chronic exposures, with a greater incidence in males than in females.

#### Mechanistic Evidence

No mechanistic evidence is available for liver and urinary bladder effects.

#### Summary of Other Toxicity Data

Based on lack of consistency and lack of progression, the available evidence does not support liver and urinary bladder effects, respectively, as potential human hazards of tert-butanol exposure.

Table B-6 Changes in kidney weight in animals following exposure to tert-butanol

Reference and study design | Results
Kidney weight (percentage change as compared to control)
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: ≈ 10 wk (4 wk prior to mating through PND 21) | Males
| Dose mg/kg-d | Left absolute weight | Left relative weight | | Right absolute weight | Right relative weight
| 0 | 0 | 0 | | 0 | 0
| 64 | 6 | 8 | | 6 | 8
| 160 | 9 | 14^*^ | | 6 | 11^*^
| 400 | 12^*^ | 14^*^ | | 14^*^ | 17^*^
| 1,000 | 18^*^ | 28^*^ | | 20^*^ | 31^*^
| Females
| Dose mg/kg-d | Left absolute weight | Left relative weight | | Right absolute weight | Right relative weight
| 0 | 0 | 0 | | 0 | 0
| 64 | −1 | −2 | | 2 | 0
| 160 | 0 | 0 | | 1 | 0
| 400 | 3 | 2 | | 4 | 2
| 1,000 | 4 | 0 | | 7 | 2
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Males | | | Females
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 0 | 0 | 0 | 0 | 0 | 0
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 230 | 12^*^ | 19^*^ | 290 | 19^*^ | 17^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 490 | 17^*^ | 26^*^ | 590 | 16^*^ | 15^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 840 | 16^*^ | 32^*^ | 850 | 29^*^ | 28^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 1,520 | 26^*^ | 54^*^ | 1,560 | 39^*^ | 40^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water 0, 2.5, 5, 10, 20, or 40 mg/mL; M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 3,610 | All dead | All dead | 3,620 | 36^*^ | 81^*^
NTP (1995); B6C3F_1_ mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 350, 640, 1,590, 3,940, or 8,210^a^ mg/kg-d; F: 0, 500, 820, 1,660, 6,430, or 11,620^a^ mg/kg-d; 13 wk | Males | | | Females
| Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
| 0 | 0 | 0 | 0 | 0 | 0
| 350 | 1 | 1 | 500 | 0 | −3
| 640 | 3 | 2 | 820 | −3 | −1
| 1,590 | 2 | 8 | 1,660 | 1 | 0
| 3,940 | 6 | 22^*^ | 6,430 | 6 | 15^*^
| 8,210 | 0 | 48^*^ | 11,620 | 12^*^ | 35^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Males | | | Females
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 0 | 0 | 0 | 0 | 0 | 0
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 90 | 4 | 8 | 180 | 8^*^ | 14^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 200 | 11 | 15^*^ | 330 | 18^*^ | 21^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 420 | 7 | 20^*^ | 650 | 22^*^ | 42^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Only rats sacrificed at 15 mo were evaluated for organ weights.
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273, or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported; Right kidney weights measured | | Males | | | Females
| Concentration mg/m^3^ | Absolute weight | Relative weight | | Absolute weight | Relative weight
| 0 | 0 | 0 | | 0 | 0
| 406 | 1 | 1 | | −4 | −1
| 824 | −2 | −1 | | 0 | 1
| 1,643 | 3 | 2 | | 4 | 4
| 3,273 | 11^*^ | 8^*^ | | 2 | 2
| 6,368 | 9.8^*^ | 9^*^ | | 4 | 9^*^
NTP (1997); B6C3F_1_ mouse; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273 or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported; Right kidney weights measured | | Males | | | Females
| Concentration mg/m^3^ | Absolute weight | Relative weight | | Absolute weight | Relative weight
| 0 | 0 | 0 | | 0 | 0
| 406 | −6 | −4 | | 1 | −3
| 824 | −1 | 3 | | 5 | 9
| 1,643 | 4 | 3 | | 1 | −2
| 3,273 | −10 | −3 | | 0 | 7
| 6,368 | 3 | 6 | | 3 | 15^*^

F = female; M = male.

* Statistically significant p ≤ 0.05 as determined by the study authors.

a The high-dose group had an increase in mortality.

Percentage change compared to control = (treated value − control value) ÷ control value × 100.

Conversions from drinking water concentrations to mg/kg-d performed by study authors.

Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

Table B-7 Changes in liver weight in animals following exposure to tert-butanol

Reference and study design | Results
Acharya et al. (1995); Wistar rat; 5–6 males/treatment; Drinking water (0 or 0.5%), 0 or 575 mg/kg-d; 10 wk | No significant treatment-related effects (results were only provided in a figure).
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | Percentage change compared to control
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | Males | | | Females
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | 0 | - | - | 0 | - | -
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | 64 | −1 | 0 | 64 | −4 | −4
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | 160 | −3 | 1 | 160 | −7 | −5
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | 400 | −2 | −1 | 400 | 2 | 1
Huntingdon Life Sciences (2004); Sprague-Dawley rat; 12/sex/treatment; Gavage 0, 64, 160, 400, or 1,000 mg/kg-d; M: 9 wk beginning 4 wk prior to mating; F: 4 wk prior to mating through PND21 | 1,000 | 8 | 16^*^ | 1,000 | 8 | 3
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | Percentage change compared to control
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | Males | | | Females
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 0 | - | - | 0 | - | -
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 230 | −2 | 4 | 290 | 11^*^ | 9^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 490 | 1 | 8^*^ | 590 | 10^*^ | 9^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 840 | 5 | 20^*^ | 850 | 12^*^ | 11^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 1,520 | 8 | 31^*^ | 1,560 | 15^*^ | 16^*^
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, 3,620^a^ mg/kg-d; 13 wk | 3,610 | All dead | All dead | 3,620 | 9^*^ | 41^*^
NTP (1995); B6C3F_1_ mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 350, 640, 1,590, 3,940, or 8,210^a^ mg/kg-d; F: 0, 500, 820, 1,660, 6,430, or 11,620^a^ mg/kg-d; 13 wk | Percentage change compared to control
| Males | | | Females
| Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
| 0 | - | - | 0 | - | -
| 350 | 2 | 3 | 500 | −1 | −4
| 640 | −1 | −2 | 820 | −5 | −3
| 1,590 | −1 | 5 | 1,660 | −8 | −9^*^
| 3,940 | 0 | 14^*^ | 6,430 | −2 | 6
| 8,210 | −16 | 22^*^ | 11,620 | −6 | 13^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Percentage change compared to control
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Males | | | Females
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Dose mg/kg-d | Absolute weight | Relative weight | Dose mg/kg-d | Absolute weight | Relative weight
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 0 | - | - | 0 | - | -
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 90 | 2 | 7 | 180 | −14^*^ | −8
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 200 | 8 | 11 | 330 | −3 | −1
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | 420 | 1 | 14^*^ | 650 | −6 | 9^*^
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5 or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | Only animals sacrificed at 15 mo were evaluated for organ weights. Organ weights were not measured in the 2-yr mouse study.
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273 or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | Percentage change compared to control
| | | Males | | Females
| Concentration mg/m^3^ | | Absolute weight | Relative weight | Absolute weight | Relative weight
| 0 | | - | - | - | -
| 406 | | −8 | −8 | 0 | 3
| 824 | | −2 | −1 | 0 | 0
| 1,643 | | 1 | −1 | 3 | 2
| 3,273 | | 10 | 7 | 9 | 9^*^
| 6,368 | | 5 | 5 | 4 | 8^*^
NTP (1997); B6C3F_1_ mouse; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273 or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | Percentage change compared to control
| | | Males | | Females
| Concentration mg/m^3^ | | Absolute weight | Relative weight | Absolute weight | Relative weight
| 0 | | - | - | - | -
| 406 | | −1 | 0 | 1 | −4
| 824 | | 4 | 9 | 1 | 5
| 1,643 | | 7 | 5 | 5 | 1
| 3,273 | | −8 | −2 | 2 | 9^*^
| 6,368 | | 5 | 7 | 8 | 21^*^

* Statistically significant p ≤ 0.05 as determined by study authors.

a The high dose group had an increase in mortality.

Conversions from drinking water concentrations to mg/kg-d performed by study authors.

Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

Percentage change compared to control = (treated value − control value) ÷ control value × 100.

Table B-8 Changes in liver histopathology in animals following exposure to tert-butanol

Reference and study design | Results
Acharya et al. (1997); Acharya et al. (1995); Wistar rat; 5−6 males/treatment; Drinking water (0, 0.5%), 0 or 575 mg/kg-d; 10 wk | ↑ liver glycogen (~sevenfold)^a^; ↑ incidence of centrilobular necrosis, vacuolation of hepatocytes, loss of hepatocyte architecture, peripheral proliferation, and lymphocyte infiltration (incidences and results of statistical tests not reported).
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^b^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^b^ mg/kg-d; 13 wk | No treatment-related effects observed.
NTP (1995); B6C3F_1_ mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 350, 640, 1,590, 3,940, or 8,210^b^ mg/kg-d; F: 0, 500, 820, 1,660, 6,430, or 11,620^b^ mg/kg-d; 13 wk | No treatment-related effects observed.
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^b^ mg/kg-d; F: 0, 180, 330, or 650^b^ mg/kg-d; 2 yr | No treatment-related effects observed.
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Males | | Females
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Dose (mg/kg-d) | Incidence of fatty change | Dose (mg/kg-d) | Incidence of fatty change
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 0 | 12/59 | 0 | 11/60
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 540 | 5/60 | 510 | 8/60
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 1,040 | 8/59 | 1,020 | 8/60
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^b^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 2,070 | 29/59^a^ | 2,110 | 6/60
NTP (1997); F344/N rat; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273 or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | No treatment-related effects observed in the high-dose group (only treatment group with liver endpoints evaluated).
NTP (1997); B6C3F_1_ mouse; 10/sex/treatment; Inhalation analytical concentration: 0, 134, 272, 542, 1,080, or 2,101 ppm (0, 406, 824, 1,643, 3,273 or 6,368 mg/m^3^) (dynamic whole-body chamber); 6 h/d, 5 d/wk; 13 wk; Generation method (Sonimist ultrasonic spray nozzle nebulizer), analytical concentration and method were reported | Authors stated that there was no treatment-related microscopic changes, but data were not provided.

a Statistically significant p ≤ 0.05 as determined by the study authors.

b The high dose group had an increase in mortality.

Conversions from drinking water concentrations to mg/kg-d were performed by the study authors.

Conversion from ppm to mg/m^3^ is 1 ppm = 3.031 mg/m^3^.

Table B-9 Changes in urinary bladder histopathology in animals following oral exposure to tert-butanol

Reference and study design | Results
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Incidence (severity)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Males | | | Females
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Dose (mg/kg-d) | | Transitional epithelial hyperplasia | Dose mg/kg-d | Transitional epithelial hyperplasia
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 0 | | 0/10 | 0 | 0/10
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 230 | | Not evaluated | 290 | Not evaluated
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 490 | | Not evaluated | 590 | Not evaluated
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 840 | | 0/10 | 850 | Not evaluated
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 1,520 | | 1/10 (3.0) | 1,560 | 0/10
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | 3,610 | | 7/10^*^ (2.9) | 3,620 | 3/10 (2.0)
NTP (1995); F344/N rat; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 230, 490, 840, 1,520, or 3,610^a^ mg/kg-d; F: 0, 290, 590, 850, 1,560, or 3,620^a^ mg/kg-d; 13 wk | Severity: 1 = minimal, 2 = mild, 3 = moderate, 4 = marked
NTP (1995); B6C3F_1_ mouse; 10/sex/treatment; Drinking water (0, 2.5, 5, 10, 20, or 40 mg/mL); M: 0, 350, 640, 1,590, 3,940, or 8,210^a^ mg/kg-d; F: 0, 500, 820, 1,660, 6,430, or 11,620^a^ mg/kg-d; 13 wk | Incidence (severity)
| Males | | | Females
| Dose mg/kg-d | Transitional epithelial hyperplasia | Inflammation | Dose mg/kg-d | Transitional epithelial hyperplasia | Inflammation
| 0 | 0/10 | 0/10 | 0 | 0/10 | 0/10
| 350 | Not evaluated | | 500 | 0/10 | 0/10
| 640 | Not evaluated | | 820 | Not evaluated
| 1,590 | 0/10 | 0/10 | 1,660 | Not evaluated
| 3,940 | 6/10^*^ (1.3) | 6/10^*^ (1.3) | 6,430 | 0/10 | 0/10
| 8,210 | 10/10^*^ (2.0) | 10/10^*^ (2.3) | 11,620 | 3/9 (2.0) | 6/9^*^ (1.2)
| Severity: 1 = minimal, 2 = mild, 3 = moderate, 4 = marked
NTP (1995); F344/N rat; 60/sex/treatment (10/sex/treatment evaluated at 15 mo); Drinking water (0, 1.25, 2.5, 5, or 10 mg/mL); M: 0, 90, 200, or 420^a^ mg/kg-d; F: 0, 180, 330, or 650^a^ mg/kg-d; 2 yr | No treatment-related effects observed.
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Incidence (severity):
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Males | | | Females
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Dose mg/kg-d | Transitional epithelial hyperplasia | Inflammation | Dose mg/kg-d | Transitional epithelial hyperplasia | Inflammation
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 0 | 1/59 (2.0) | 0/59 | 0 | 0/59 | 0/59
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 540 | 3/59 (1.7) | 3/59 (1.7) | 510 | 0/60 | 0/60
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 1,040 | 1/58 (1.0) | 1/58 (1.0) | 1,020 | 0/59 | 0/59
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | 2,070 | 17/59^*^ (1.8) | 37/59^*^ (2.0) | 2,110 | 3/57 (1.0) | 4/57^*^ (2.0)
NTP (1995); B6C3F_1_ mouse; 60/sex/treatment; Drinking water (0, 5, 10, or 20 mg/mL); M: 0, 540, 1,040, or 2,070^a^ mg/kg-d; F: 0, 510, 1,020, or 2,110 mg/kg-d; 2 yr | Severity: 1 = minimal, 2 = mild, 3 = moderate, 4 = marked

a The high dose group had an increase in mortality.

* Statistically significant p ≤ 0.05 as determined by study authors.

Conversions from drinking water concentrations to mg/kg-d were performed by the study authors.

Figure B-14 Exposure-response array of other effects following oral exposure to tert-butanol

Sources: (A) Acharva et al. (1997); Acharva et al. (1995); (B) Huntingdon Life Sciences (2004); (C) NTP (1995).

Figure B-15 Exposure-response array of other effects following inhalation exposure to tert-butanol

Source: (A) NTP (1997).

### B.2.2 Genotoxicity

The genotoxic potential of tert-butanol has been studied using a variety of assays, including bacterial reverse mutation assays, gene mutation assays, chromosomal aberrations, sister chromatid exchanges, micronucleus induction, and deoxyribonucleic acid (DNA) strand breaks and adducts. The available genotoxicity data for tert-butanol are discussed below, and the data summary is provided in Table B-10.

#### Bacterial Systems

The mutagenic potential of tert-butanol has been tested by Zeiger et al. (1987) using different Salmonella typhimurium strains both in the presence and absence of S9 metabolic activation. The preincubation assay protocol was followed. Salmonella strains TA98, TA100, TA1535, TA1537, and TA1538 were exposed to five concentrations (100, 333, 1,000, 3,333, or 10,000 μg/plate) and tested in triplicate. No mutations were observed in any of the strains tested, in either the presence or absence of S9 metabolic activation.

Conflicting results have been obtained with tert-butanol-induced mutagenicity in Salmonella strain TA102, a strain that is sensitive to damage at A-T sites inducible by oxidants and other mutagens and is excision-repair proficient. In a study by Williams-Hill et al. (1999), tert-butanol induced an increase in the number of revertants in the first three concentrations with S9 activation in a dose-response manner. The number of revertants decreased in the last two concentrations. No discussion was provided on why the revertants decreased at higher concentrations. The results of this study indicated that test strain TA102 might be a more sensitive strain for monitoring tert-butanol levels (Williams-Hill et al., 1999). In another study by McGregor et al. (2005), however, experiments were conducted on TA102 at two different laboratories using similar protocols. tert-butanol was dissolved in dimethyl sulfoxide (DMSO) or distilled water and tested in both the presence and absence of S9 metabolic activation. No statistically significant increase in mutants was observed in either solvent medium.

Mutagenicity of tert-butanol has been studied in other systems, including Neurospora crassa and Saccharomyces cerevisiae. Yeast strain Neurospora crassa at the ad-3A locus (allele 38701) was used to test the mutagenic activity of tert-butanol at a concentration of 1.75 mol/L for 30 minutes. tert-butanol did not induce reverse mutations in the tested strain at the exposed concentration (Dickev et al., 1949). tert-butanol without exogenous metabolic activation, however, significantly increased the frequency of petite mutations (the mitochondrial DNA deletion rho−) in Saccharomyces cerevisiae laboratory strains K5-A5, MMY1, D517-4B, and DS8 (Jiménez et al., 1988). This effect on mitochondrial DNA, also observed with ethanol and other solvents, was attributed by the study authors to the alteration in the lipid composition of mitochondrial membranes, and mitochondrial DNA’s close association could be affected by membrane composition (Jiménez et al., 1988).

#### In Vitro Mammalian Studies

To understand the role of tert-butanol-induced genotoxicity in mammalian systems, in vitro studies have been conducted in different test systems and assays. tert-butanol was tested to evaluate its ability to induce forward mutations at the thymidine kinase (tk) locus in the L5178Y tk^±^ mouse lymphoma cells using forward mutation assay. Experiments were conducted in both the presence and absence of S9 metabolic activation. The mutant frequency was calculated using the ratio of mutant clones per plate/total clones per plate × 200. tert-butanol did not reliably increase the frequency of forward mutations in L5178Y tk^±^ mouse lymphoma cells with or without metabolic activation, although one experiment without addition of S9 yielded a small (1.7-fold) increase in mutant fraction at the highest tested concentration [5,000 μg/mL; Mcgregor et al. (1988)].

To further determine potential DNA or chromosomal damage induced by tert-butanol in in vitro systems, NTP (1995) studied sister chromatid exchanges and chromosomal aberrations. Chinese hamster ovary (CHO) cells were exposed to tert-butanol in both the presence and absence of S9 activation at concentrations of 160–5,000 μg/mL for 26 hours. tert-butanol did not induce sister chromatid exchanges at any concentration tested, although in one experiment, the percentage of relative change of sister chromatid exchanges per chromosome scored slightly increased. The same authors also studied the effect of tert-butanol on chromosomal aberration formation. CHO cells were exposed to four concentrations (160, 500, 1,600, or 5,000 μg/mL) of tert-butanol in both the presence and absence of S9. No significant increase in chromosomal aberration was observed at any concentration tested. Of note is that, due to severe toxicity at the highest concentration (5,000 μg/mL), only 13 metaphase cells were scored instead of 100 in the chromosomal aberration assay.

Sgambato et al. (2009) examined the effects of tert-butanol on DNA damage using a normal diploid rat fibroblast cell line. Cells were treated with 0- to 100-mM tert-butanol for 48 hours to determine the half-maximal inhibitory concentration (IC_50_; 0.44 ± 0.2 mM). The 48-hour IC_50_ concentration then was used to determine DNA content, cell number, and phases of the cell cycle after 24 and 48 hours of exposure. Total protein and DNA oxidative damage also were measured. A comet assay was used to evaluate DNA fragmentation at time 0 and after 30 minutes, 4 hours, or 12 hours of exposure to the IC_50_ concentration. tert-butanol inhibited cell division as measured by the number of cells after 24 and 48 hours of exposure at IC_50_ concentrations and with concentrations at 1/10th the IC_50_. Cell death did not increase, suggesting a reduction in cell number due to reduced replication rather than to cytotoxicity. tert-butanol caused an accumulation in the G_0_/G_1_ phase of replication, related to different effects on the expression of the cyclin D1, p27Kip1, and p53 genes. An initial increase in DNA damage as measured by nuclear fragmentation was observed at 30 minutes. The DNA damage declined drastically after 4 hours and disappeared almost entirely after 12 hours of exposure to tert-butanol. This reduction in the extent of DNA fragmentation after the initial increase is likely the result of an efficient DNA repair mechanism activated by cells following DNA damage induced by tert-butanol.

DNA damage caused by tert-butanol was determined by single-cell gel electrophoresis (comet assay) in human promyelocytic leukemia (HL-60) cells. The cells were exposed to concentrations ranging from 1 to 30 mmol/L for 1 hour, and 100 cells were evaluated for DNA fragmentation. A dose-dependent increase in DNA damage was observed between 1 and 30 mmol/L. No cytotoxicity was observed at the concentrations tested (Tang et al., 1997).

#### In Vivo Mammalian Studies

Few in vivo studies are available to understand the role of tert-butanol on genotoxicity. The National Toxicology Program (NTP) studied the effect of tert-butanol in a 13-week toxicity study (NTP, 1995). Peripheral blood samples were obtained from male and female B6C3F_1_ mice exposed to tert-butanol in drinking water at doses of 3,000–40,000 ppm. Slides were prepared to determine the frequency of micronuclei in 10,000 normochromatic erythrocytes. In addition, the percentage of polychromatic erythrocytes among the total erythrocyte population was determined. No increase in micronucleus induction in peripheral blood lymphocytes was observed either in male or female B6C3F_1_ mice exposed for 13 weeks to tert-butanol in drinking water at concentrations as high as 40,000 ppm [2,110 mg/kg-day; NTP (1997, 1995)]. Furthermore, no induction of micronuclei in polychromatic erythrocytes was observed in bone marrow cells of male rats receiving intraperitoneal injections (NTP, 1997).

Male Kunming mice (eight per treatment) were administered 0, 0.099, 0.99, 10, 101, or 997 μg/kg BW ^14^C-tert-butanol in saline via gavage with specific activity ranging from 1.60 to 0.00978 mCi/mol (Yuan et al., 2007). Animals were sacrificed 6 hours after exposure, and liver, kidney, and lung were collected. Tissues were prepared for DNA isolation with samples from the same organs from every two mice combined. DNA adducts were measured using accelerated mass spectrometry. The results of this study showed a dose-response increase in DNA adducts in all three organs measured, although the methodology used to detect DNA adducts is considered sensitive but could be nonspecific. The authors stated that their study was the first to find that tert-butanol formed DNA adducts in mouse liver, lung, and kidney. Because this is a single and first-time study, further validation of it will provide certainty in understanding the mechanism of tert-butanol-induced DNA adducts.

Table B-10 Summary of genotoxicity (both in vitro and in vivo) studies of tert-butanol

Test system | Dose/concentration | Results^a^ | | Comments | Reference
Test system | Dose/concentration | −S9 | +S9 | Comments | Reference
Bacterial systems
Reverse mutation assay Salmonella typhimurium (TA98, TA100, TA1535, TA1537, TA1538) | 100, 333, 1,000, 3,333, 10,000 µg/plate | − | − | Preincubation procedure was followed; this study was part of the NTP 1995 testing results | Zeiger et al. (1987); NTP (1995)
Reverse mutation assay Salmonella typhimurium (TA102) | 1,000–4,000 µg/plate | ND | + | Only tested with S9 activation | Williams-Hill et al. (1999)
Reverse mutation assay Salmonella typhimurium (TA98, TA100, TA102, TA1535, TA1537) | 5, 15, 50, 100, 150, 200, 500, 1,000, 1,500, 2,500, 5,000 µg/plate | − | − | Experiments conducted in two different laboratories, two vehicles―distilled water and DMSO were used, different concentrations were used in experiments from different laboratories | McGregor et al. (2005)
Reverse mutation Neurospora crassa, ad-3A locus (allele 38701) | 1.75 mol/L | − | − | 84% cell death was observed; note it is a 1949 study | Dickey et al. (1949)
Mitochondrial mutation Saccharomyces cerevisiae (K5-5A, MMY1, D517-4B, and DS8) | 4.0% (vol/vol) | +^b^ | ND | Mitochondrial mutations, membrane solvent | Jiménez et al. (1988)
In vitro systems
Gene mutation assay, mouse lymphoma cells L5178Y tk^±^ | 625, 1,000, 1,250, 2,000, 3,000, 4,000, 5,000 μg/mL | − | − | Cultures were exposed for 4 h, then cultured for 2 d before plating in soft agar with or without trifluorothymidine, 3 μg/mL; this study was part of the NTP 1995 testing results | Mcgregor et al. (1988); NTP (1995)
Sister-chromatid exchange, Chinese hamster ovary cells | 160, 500, 1,600, 2,000, 3,000, 4,000, 5,000 µg/mL | − | − | This study was part of the NTP 1995 testing results | Galloway et al. (1987); NTP (1995)
Chromosomal aberrations, Chinese hamster ovary cells | 160, 500, 1,600, 2,000, 3,000, 4,000, 5,000 µg/mL | − | − | This study was part of the NTP 1995 testing results | Galloway et al. (1987); NTP (1995)
DNA damage (comet assay), rat fibroblasts | 0.44 mmol/L (IC_50_) | +^c^ | ND | Exposure duration―30 min, 4 h, 12 h; this study provides other information on the effect of cell cycle control genes and mechanism of action for TBA | Sgambato et al. (2009)
DNA damage, (comet assay), HL-60 leukemia cells | 1, 5, 10, 30 mmol/L | + | ND | Exposure duration―1 h | Tang et al. (1997)
In vivo animal studies
Micronucleus induction, B6C3F_1_ mouse peripheral blood cells | 3,000, 5,000, 10,000, 20,000, 40,000 ppm | − | | 13-wk, subchronic, drinking water study | NTP (1995)
Micronucleus induction, male rats, bone marrow cells | 39, 78, 156, 312, 625, 1,250 | − | | i.p. injections―3 times at 24-h intervals | NTP (1997)
DNA adducts, male Kunming mouse liver, kidney, and lung cells | 0.1−1,000 µg/kg body weight | + | | Gavage, 6-h exposure, DNA adduct determined by accelerator mass spectrometry | Yuan et al. (2007)

NTP = National Toxicology Program.

a + = positive; − = negative; ND = not determined.

b Effect is predicted to be due to mitochondrial membrane composition.

c DNA damage was completely reversed with increased exposure time.

### B.2.3 Summary

tert-butanol has been tested for its genotoxic potential using a variety of genotoxicity assays. In general, a positive result in the Ames assay is 73–77% predictive of a positive result in the rodent carcinogenicity assay (Kirkland et al., 2005). tert-butanol did not induce mutations in most bacterial strains; however, when tested in TA102, a strain that is sensitive to damage at A-T sites inducible by oxidants, an increase in mutants was observed at low concentrations, although conflicting results were reported in another study. Furthermore, the solvent (e.g., distilled water or DMSO) used in the genotoxicity assay could influence results. In one experiment where tert-butanol was dissolved in distilled water, a significant, dose-related increase in the number of mutants was observed, with the maximum value reaching almost twice the control value. DMSO is known to be a radical scavenger, and its presence in high concentrations might mask a mutagenic response modulated by oxidative damage. Exposure to tert-butanol did not produce reverse mutations in other species such as Neurospora crassa.

tert-butanol was tested in several human and animal in vitro mammalian systems for genotoxicity (gene mutation, sister chromatid exchanges, chromosomal aberrations, and DNA damage). No increase in gene mutations was observed in mouse lymphoma cells (L5178Y tk^±^). These specific locus mutations in mammalian cells are used to demonstrate and quantify genetic damage, thereby confirming or extending the data obtained in the more widely used bacterial cell tests. Sister chromatid exchanges or chromosomal aberrations were not observed in CHO cells in response to tert-butanol treatment. DNA damage was detected using a comet assay in both rat fibroblasts and HL-60 leukemia cells with either an increase in DNA fragmentation at the beginning of the exposure or dose-dependent increase in DNA damage. An initial increase in DNA damage was observed at 30 minutes that declined drastically following 4 hours of exposure and disappeared almost entirely after 12 hours of exposure to tert-butanol. This reduction in the extent of DNA fragmentation after an initial increase is likely the result of an efficient DNA repair mechanism activated by cells following DNA damage induced by tert-butanol. A dose-dependent increase in DNA damage was observed in human cells tested; however, because the exposure occurred for only 1 hour in this study, whether DNA-repair mechanisms would occur after a longer period of observation cannot be discerned.

Limited in vivo animal studies have been conducted on DNA adduct formation and micronucleus induction. A dose-response increase in DNA adducts was observed in mouse liver, kidney, and lung cells. The authors used accelerated mass spectrometry to detect DNA adducts, but the identity of these adducts was not determined. The method uses ^14^C-labeled chemical for dosing. Isolated DNA is oxidized to carbon dioxide and reduced to filamentous graphite, and the ratios of ^14^C/^12^C are measured. The ratio is then converted to DNA adducts based on nucleotide content of the DNA. Confirmation of these data will further the understanding of the mechanism of tert-butanol-induced DNA adducts. No increase in micronucleus induction was observed in mouse peripheral blood cells in a 13-week drinking water study conducted by NTP.

Overall, a limited evidence base is available for understanding the role of tert-butanol-induced genotoxicity for mode of action and carcinogenicity. The evidence base is limited in terms of either the array of genotoxicity tests conducted or the number of studies within the same type of test. In addition, the results are either conflicting or inconsistent. The test strains, solvents, or control for volatility used in certain studies are variable and could influence results. Furthermore, in some studies, the specificity of the methodology used has been challenged. Given the inconsistencies and limitations of the evidence base in terms of the methodology used, the number of studies in the overall evidence base, the coverage of studies across the genotoxicity battery, and the quality of the studies, the weight-of-evidence analysis is inconclusive. The available data do not inform a definitive conclusion on the genotoxicity of tert-butanol and therefore the potential genotoxic effects of tert-butanol cannot be discounted.