# APPENDIX A ASSESSMENTS BY OTHER NATIONAL AND INTERNATIONAL HEALTH AGENCIES

Table A-1 Health assessments and regulatory limits by other national and international health agencies

Organization | Toxicity value
National Institute of Occupational Safety and Health (NIOSH, 2007) | Recommended exposure limit―100 ppm (300 mg/m^3^) TWA for up to a 10-h workday and a 40-h workweek.
Occupational Safety and Health (OSHA, 2006) | Permissible exposure limit for general industry―100 ppm (300 mg/m^3^) TWA for an 8-h workday.
Food and Drug Administration (FDA, 2015a, b) | tert-Butyl alcohol—Indirect food additive that may be safely used in surface lubricants employed in the manufacture of metallic articles that contact food, subject to the provisions of this Section (21 Code of Federal Regulations [CFR] 178.3910); substance may be used as a defoaming agent (21 CFR 176.200).

TWA = time-weighted average.