# ABBREVIATIONS

ADAF: age-dependent adjustment factors
ATH: acute tubule hyperplasia
AIC: Akaike’s information criterion
Fe-EDTA: iron-catalyzed oxidation of ascorbic acid
atm: atmosphere
BEC: blood ethanol concentration
BMC: benchmark concentration
BMCL: benchmark concentration lower confidence level
BMCL_ADJ_: duration-adjusted benchmark concentration lower confidence level
BMCL_HEC_: benchmark concentration lower confidence limit, human equivalent concentration
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDL_BMR_: benchmark dose lower confidence limit, benchmark response
BMDS: Benchmark Dose Software
BMDU: benchmark dose upper confidence limit
BMR: benchmark response
BW: body weight
BW^3/4^: body weight to the ¾ power
BW_a_: animal body weight
BW_h_: human body weight
CAAC: Chemical Assessment Advisory Committee
CAR: constitutive androstane receptor
CASRN: Chemical Abstracts Service registry number
C_avg_: average blood concentration
CFR: Code of Federal Regulations
CHO: Chinese hamster ovary (cell line)
CL: confidence limit
CL: liver concentration
CNS: central nervous system
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
CSL: continuous simulation language
CVL: concentration in the venous blood leaving the liver
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
df: degrees of freedom
DMSO: dimethylsulfoxide
DNA: deoxyribonucleic acid
EHC: Environmental Health Criteria
ELISA: enzyme-linked immunosorbent assay
EPA: Environmental Protection Agency
ETBE: ethyl tertiary butyl ether
F: female
FDA: Food and Drug Administration
GD: gestation day
GLP: good laboratory practice
Hb/g-A: animal blood:gas partition coefficient
Hb/g-H: human blood:gas partition coefficient
HBA: 2 hydroxyisobutyrate
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
HL-60: human promyelocytic leukemia
i.p.: intraperitoneal
i.v.: intravenous
IARC: International Agency for Research on Cancer
IC_50_: half-maximal inhibitory concentration
IRIS: Integrated Risk Information System
JPEC: Japan Petroleum Energy Center
Km: Michaelis-Menten constant
LA: animal blood:air partition concentration
LH: human blood:air partition concentration
LOAEL: lowest-observed-adverse-effect level
M: male
M_avg_: average rate of metabolism
MFO: mixed function oxidase
MPD: 2-methyl-1,2-propanediol
mRNA: messenger ribonucleic acid
MTBE: methyl tert butyl ether
NADPH: nicotinamide adenine dinucleotide phosphate
NA: not applicable
MTD: maximum tolerated dose
MW: molecular weight
NADPH: reduced form of nicotinamide adenine dinucleotide phosphate
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
OECD: Organisation for Economic Co-operation and Development
.OH: hydroxyl radical
OSF: oral slope factor
PBPK: physiologically based pharmacokinetic
PECO: populations, exposures, comparators, and outcomes
PK: pharmacokinetic
PND: postnatal day
POD: point of departure
POD_ADJ_: duration-adjusted POD
POD_HEC_: point of departure, human equivalent concentration
POD_HED_: point of departure, human equivalent dose
QA: quality assurance
QSAR: quantitative structure-activity relationship
QA: quality assurance
RfC: inhalation reference concentration
RfD: oral reference dose
rho: Spearman rank correlation coefficient
RTR: route-to-route
SAB: Science Advisory Board
SD: standard deviation
SULT1A1: sulfotransferase 1A1
T3: triiodothyronine
T4: thyroxine
TBA: tert-butyl alcohol; tert-butanol
tk: thymidine kinase
TRI: Toxics Release Inventory
TSCA: Toxic Substances Control Act
TSCATS: Toxic Substances Control Act Test Submissions
TSH: thyroid-stimulating hormone
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
U.S.: United States
w/v: weight by volume
WHO: World Health Organization
XMET: xenobiotic metabolizing enzyme and transporter