# REFERENCES

Abdel-Hafiz, HA; Horwitz, KB. (2014). Post-translational modifications of the progesterone receptors [Review]. J Steroid Biochem Mol Biol 140: 80–89. 10.1016/j.jsbmb.2013.12.008.24333793
Adinehzadeh, M; Reo, NV. (1998). Effects of peroxisome proliferators on rat liver phospholipids: sphingomyelin degradation may be involved in hepatotoxic mechanism of perfluorodecanoic acid. Chem Res Toxicol 11: 428–440. 10.1021/tx970155t.9585473
Aimuzi, R; Luo, K; Chen, Q; Wang, H; Feng, L; Ouyang, F; Zhang, J. (2019). Perfluoroalkyl and polyfluoroalkyl substances and fetal thyroid hormone levels in umbilical cord blood among newborns by prelabor caesarean delivery. Environ Int 130: 104929. 10.1016/j.envint.2019.104929.31228788
Aimuzi, R; Luo, K; Huang, R; Huo, XN; Nian, M; Ouyang, FX; Du, YT; Feng, LP; Wang, WY; Zhang, J. (2020). Perfluoroalkyl and polyfluroalkyl substances and maternal thyroid hormones in early pregnancy. Environ Pollut 264: 114557. 10.1016/j.envpol.2020.114557.32388293
Al-Eryani, L; Wahlang, B; Falkner, KC; Guardiola, JJ; Clair, HB; Prough, RA; Cave, M. (2015). Identification of Environmental Chemicals Associated with the Development of Toxicant-associated Fatty Liver Disease in Rodents. Toxicol Pathol 43: 482–497. 10.1177/0192623314549960.25326588
Alberti, KG; Eckel, RH; Grundy, SM; Zimmet, PZ; Cleeman, JI; Donato, KA; Fruchart, JC; James, WP; Loria, CM; Smith, SC. (2009). Harmonizing the metabolic syndrome: A joint interim statement of the International Diabetes Federation Task Force on Epidemiology and Prevention; National Heart, Lung, and Blood Institute; American Heart Association; World Heart Federation; International Atherosclerosis Society; and International Association for the Study of Obesity. Circulation 120: 1640–1645. 10.1161/CIRCULATIONAHA.109.192644.19805654
Alexander, EK; Pearce, EN; Brent, GA; Brown, RS; Chen, H; Dosiou, C; Grobman, W; Laurberg, P; Lazarus, JH; Mandel, SJ; Peeters, R; Sullivan, S. (2017). 2017 Guidelines of the American Thyroid Association for the diagnosis and management of thyroid disease during pregnancy and the postpartum. Thyroid 27: 315–389. 10.1089/thy.2016.0457.28056690
Amin, K. (2012). The role of mast cells in allergic inflammation. Respir Med 106: 9–14. 10.1016/j.rmed.2011.09.007.22112783
Ammitzbøll, C; Börnsen, L; Petersen, ER; Oturai, AB; Søndergaard, HB; Grandjean, P; Sellebjerg, F. (2019). Perfluorinated substances, risk factors for multiple sclerosis and cellular immune activation. J Neuroimmunol 330: 90–95. 10.1016/j.jneuroim.2019.03.002.30852181
Anderson, RH; Long, GC; Porter, RC; Anderson, JK. (2016). Occurrence of select perfluoroalkyl substances at U.S. Air Force aqueous film-forming foam release sites other than fire-training areas: Field-validation of critical fate and transport properties. Chemosphere 150: 678–685. 10.1016/j.chemosphere.2016.01.014.26786021
Angrish, MM; Kaiser, JP; Mcqueen, CA; Chorley, BN. (2016). Tipping the balance: Hepatotoxicity and the 4 apical key events of hepatic steatosis [Review]. Toxicol Sci 150: 261–268. 10.1093/toxsci/kfw018.26980302
Arand, M; Coughtrie, MW; Burchell, B; Oesch, F; Robertson, LW. (1991). Selective induction of bilirubin UDP-glucuronosyl-transferase by perfluorodecanoic acid. Chem Biol Interact 77: 97–105. 10.1016/0009-2797(91)90008-U.1898504
ATSDR (Agency for Toxic Substances and Disease Registry). (2018a). An overview of perfluoroalkyl and polyfluoroalkyl substances and interim guidance for clinicians responding to patient exposure concerns. Interim guidance revised 5/7/2018. https://stacks.cdc.gov/view/cdc/77114.
ATSDR (Agency for Toxic Substances and Disease Registry). (2018b). Toxicological profile for perfluoroalkyls. Draft for public comment [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/toxprofiles/tp200.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
ATSDR (Agency for Toxic Substances and Disease Registry). (2024). PFAS: Information for clinicians [Fact Sheet]. https://www.atsdr.cdc.gov/pfas/docs/PFAS-info-for-clinicians-508.pdf.
Averina, M; Brox, J; Huber, S; Furberg, AS. (2021). Exposure to perfluoroalkyl substances (PFAS) and dyslipidemia, hypertension and obesity in adolescents. The Fit Futures study. Environ Res 195: 110740. 10.1016/j.envres.2021.110740.33460636
Bach, CC; Bech, BH; Nohr, EA; Olsen, J; Matthiesen, NB; Bonefeld-Jørgensen, EC; Bossi, R; Henriksen, TB. (2016). Perfluoroalkyl acids in maternal serum and indices of fetal growth: The Aarhus Birth Cohort. Environ Health Perspect 124: 848–854. 10.1289/ehp.1510046.26495857
Bach, CC; Bech, BH; Nohr, EA; Olsen, J; Matthiesen, NB; Bossi, R; Uldbjerg, N; Bonefeld-Jørgensen, EC; Henriksen, TB. (2015). Serum perfluoroalkyl acids and time to pregnancy in nulliparous women. Environ Res 142: 535–541. 10.1016/j.envres.2015.08.007.26282225
Bach, CC; Matthiesen, NB; Olsen, J; Henriksen, TB. (2018). Conditioning on parity in studies of perfluoroalkyl acids and time to pregnancy: An example from the Danish national birth cohort. Environ Health Perspect 126: 117003. 10.1289/EHP1493.30417653
Baduel, C; Paxman, CJ; Mueller, JF. (2015). Perfluoroalkyl substances in a firefighting training ground (FTG), distribution and potential future release. J Hazard Mater 296: 46–53. 10.1016/j.jhazmat.2015.03.007.25966923
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Bao, J; Shao, LX; Liu, Y; Cui, SW; Wang, X; Lu, GL; Wang, X; Jin, YH. (2022). Target analysis and suspect screening of per- and polyfluoroalkyl substances in paired samples of maternal serum, umbilical cord serum, and placenta near fluorochemical plants in Fuxin, China. Chemosphere 307: 135731. 10.1016/j.chemosphere.2022.135731.35843426
Bao, WW; Qian, ZM; Geiger, SD; Liu, E; Liu, Y; Wang, SQ; Lawrence, WR; Yang, BY; Hu, LW; Zeng, XW; Dong, GH. (2017). Gender-specific associations between serum isomers of perfluoroalkyl substances and blood pressure among Chinese: Isomers of C8 Health Project in China. Sci Total Environ 607-608: 1304–1312. 10.1016/j.scitotenv.2017.07.124.28738507
Barber, JL; Berger, U; Chaemfa, C; Huber, S; Jahnke, A; Temme, C; Jones, KC. (2007). Analysis of per- and polyfluorinated alkyl substances in air samples from Northwest Europe. J Environ Monit 9: 530–541. 10.1039/b701417a.17554424
Barrett, ES; Chen, C; Thurston, SW; Haug, LS; Sabaredzovic, A; Fjeldheim, FN; Frydenberg, H; Lipson, SF; Ellison, PT; Thune, I. (2015). Perfluoroalkyl substances and ovarian hormone concentrations in naturally cycling women. Fertil Steril 103: 1261–1270.e1263. 10.1016/j.fertnstert.2015.02.001.25747128
Batt, AM; Ferrari, L. (1995). Manifestations of chemically-induced liver-damage. Clin Chem 41: 1882–1887.7497649
Beck, IH; Timmermann, CAG; Nielsen, F; Schoeters, G; Jøhnk, C; Kyhl, HB; Høst, A; Jensen, TK. (2019). Association between prenatal exposure to perfluoroalkyl substances and asthma in 5-year-old children in the Odense Child Cohort. Environ Health 18: 97. 10.1186/s12940-019-0541-z.31730470
Berg, V; Nøst, TH; Hansen, S; Elverland, A; Veyhe, AS; Jorde, R; Odland, JØ; Sandanger, TM. (2015). Assessing the relationship between perfluoroalkyl substances, thyroid hormones and binding proteins in pregnant women; a longitudinal mixed effects approach. Environ Int 77: 63–69. 10.1016/j.envint.2015.01.007.25647630
Berg, V; Nøst, TH; Pettersen, RD; Hansen, S; Veyhe, AS; Jorde, R; Odland, JØ; Sandanger, TM. (2017). Persistent organic pollutants and the association with maternal and infant thyroid homeostasis: a multipollutant assessment. Environ Health Perspect 125: 127–133. 10.1289/EHP152.27219111
Bernstein, AS; Kapraun, DF; Schlosser, PM. (2021). A Model Template Approach for Rapid Evaluation and Application of Physiologically Based Pharmacokinetic Models for Use in Human Health Risk Assessments: A Case Study on Per- and Polyfluoroalkyl Substances. Toxicol Sci 182: 215–228. 10.1093/toxsci/kfab063.34077538
Bijland, S; Rensen, PCN; Pieterman, EJ; Maas, ACE; van Der Hoorn, JW; van Erk, MJ; Havekes, LM; Willems van Dijk, K; Chang, SC; Ehresman, DJ; Butenhoff, JL; Princen, HMG. (2011). Perfluoroalkyl sulfonates cause alkyl chain length-dependent hepatic steatosis and hypolipidemia mainly by impairing lipoprotein production in APOE*3-Leiden CETP mice. Toxicol Sci 123: 290–303. 10.1093/toxsci/kfr142.21705711
Birukov, A; Andersen, LB; Andersen, MS; Nielsen, JH; Nielsen, F; Kyhl, HB; Jørgensen, JS; Grandjean, P; Dechend, R; Jensen, TK. (2021). Exposure to perfluoroalkyl substances and blood pressure in pregnancy among 1436 women from the Odense Child Cohort. Environ Int 151: 106442. 10.1016/j.envint.2021.106442.33610053
Biton, Y; Goldenberg, I; Kutyifa, V; Baman, J. R.; Solomon, S; Moss, AJ; Szepietowska, B; Mcnitt, S; Polonsky, B; Zareba, W; Barsheshet, A. (2016). Relative Wall Thickness and the Risk for Ventricular Tachyarrhythmias in Patients With Left Ventricular Dysfunction. J Am Coll Cardiol 67: 303–312. 10.1016/j.jacc.2015.10.076.26796396
Bjerregaard-Olesen, C; Bach, CC; Long, M; Wielsøe, M; Bech, BH; Henriksen, TB; Olsen, J; Bonefeld-Jørgensen, EC. (2019). Associations of Fetal Growth Outcomes with Measures of the Combined Xenoestrogenic Activity of Maternal Serum Perfluorinated Alkyl Acids in Danish Pregnant Women. Environ Health Perspect 127: 17006. 10.1289/EHP1884.30676078
Blake, BE; Pinney, SM; Hines, EP; Fenton, SE; Ferguson, KK. (2018). Associations between longitudinal serum perfluoroalkyl substance (PFAS) levels and measures of thyroid hormone, kidney function, and body mass index in the Fernald Community Cohort. Environ Pollut 242: 894–904. 10.1016/j.envpol.2018.07.042.30373035
Blomberg, AJ; Shih, YH; Messerlian, C; Jørgensen, LH; Weihe, P; Grandjean, P. (2021). Early-life associations between per- and polyfluoroalkyl substances and serum lipids in a longitudinal birth cohort. Environ Res 200: 111400. 10.1016/j.envres.2021.111400.34081971
Bloom, MS; Commodore, S; Ferguson, PL; Neelon, B; Pearce, JL; Baumer, A; Newman, RB; Grobman, W; Tita, A; Roberts, J; Skupski, D; Palomares, K; Nageotte, M; Kannan, K; Zhang, C; Wapner, R; Vena, JE; Hunt, KJ. (2022). Association between gestational PFAS exposure and Children's adiposity in a diverse population. Environ Res 203: 111820. 10.1016/j.envres.2021.111820.34343551
Bloom, MS; Kannan, K; Spliethoff, HM; Tao, L; Aldous, KM; Vena, JE. (2010). Exploratory assessment of perfluorinated compounds and human thyroid function. Physiol Behav 99: 240–245. 10.1016/j.physbeh.2009.02.005.19419669
Boettiger, EG. (1946). Changes in the glycogen and water content of the rat uterus. Journal of Cellular and Comparative Physiology 27: 9–14. 10.1002/jcp.1030270103.21021854
Bookstaff, RC; Moore, RW; Ingall, GB; Peterson, RE. (1990). Androgenic deficiency in male rats treated with perfluorodecanoic acid. Toxicol Appl Pharmacol 104: 322–333. 10.1016/0041-008X(90)90306-F.2363183
Boone, L; Meyer, D; Cusick, P; Ennulat, D; Bolliger, AP; Everds, N; Meador, V; Elliott, G; Honor, D; Bounous, D; Jordan, H. (2005). Selection and interpretation of clinical pathology indicators of hepatic injury in preclinical studies [Review]. Vet Clin Pathol 34: 182–188. 10.1111/j.1939-165X.2005.tb00041.x.16134065
Borghese, MM; Liang, CL; Owen, J; Fisher, M. (2022). Individual and mixture associations of perfluoroalkyl substances on liver function biomarkers in the Canadian Health Measures Survey. Environ Health 21: 85. 10.1186/s12940-022-00892-6.36104725
Boros, DL; Revankar, SG. (2017). Granulomatous diseases. 2017.
Boujrad, N; Vidic, B; Gazouli, M; Culty, M; Papadopoulos, V. (2000). The peroxisome proliferator perfluorodecanoic acid inhibits the peripheral-type benzodiazepine receptor (PBR) expression and hormone-stimulated mitochondrial cholesterol transport and steroid formation in Leydig cells. Endocrinology 141: 3137–3148. 10.1210/endo.141.9.7678.10965884
Bräunig, J; Baduel, C; Heffernan, A; Rotander, A; Donaldson, E; Mueller, JF. (2017). Fate and redistribution of perfluoroalkyl acids through AFFF-impacted groundwater. Sci Total Environ 596-597: 360–368. 10.1016/j.scitotenv.2017.04.095.28441576
Bretveld, RW; Thomas, CMG; Scheepers, PTJ; Zielhuis, GA; Roeleveld, N. (2006). Pesticide exposure: the hormonal function of the female reproductive system disrupted? [Review]. Reprod Biol Endocrinol 4: 30. 10.1186/1477-7827-4-30.16737536
Brewster, DW; Birnbaum, LS. (1989). The biochemical toxicity of perfluorodecanoic acid in the mouse is different from that of 2, 3, 7, 8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 99: 544–554. 10.1016/0041-008X(89)90161-0.2749739
Buck Louis, GM; Chen, Z; Schisterman, EF; Kim, S; Sweeney, AM; Sundaram, R; Lynch, CD; Gore-Langton, RE; Barr, DB. (2015). Perfluorochemicals and human semen quality: The LIFE Study. Environ Health Perspect 123: 57–63. 10.1289/ehp.1307621.25127343
Buck Louis, GM; Zhai, S; Smarr, MM; Grewal, J; Zhang, C; Grantz, KL; Hinkle, SN; Sundaram, R; Lee, S; Honda, M; Oh, J; Kannan, K. (2018). Endocrine disruptors and neonatal anthropometry, NICHD Fetal Growth Studies - Singletons. Environ Int 119: 515–526. 10.1016/j.envint.2018.07.024.30055518
Buck, RC; Franklin, J; Berger, U; Conder, JM; Cousins, IT; de Voogt, P; Jensen, AA; Kannan, K; Mabury, SA; van Leeuwen, SP. (2011). Perfluoroalkyl and polyfluoroalkyl substances in the environment: terminology, classification, and origins [Review]. Integr Environ Assess Manag 7: 513–541. 10.1002/ieam.258.21793199
Budtz-Jørgensen, E; Grandjean, P. (2018a). Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity. PLoS ONE 13: e0205388. 10.1371/journal.pone.0205388.30339706
Budtz-Jørgensen, E; Grandjean, P. (2018b). Computational details for the paper “Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity".
Buhrke, T; Kibellus, A; Lampen, A. (2013). In vitro toxicological characterization of perfluorinated carboxylic acids with different carbon chain lengths. Toxicol Lett 218: 97–104. 10.1016/j.toxlet.2013.01.025.23391484
Cakmak, S; Lukina, A; Karthikeyan, S; Atlas, E; Dales, R. (2022). The association between blood PFAS concentrations and clinical biochemical measures of organ function and metabolism in participants of the Canadian Health Measures Survey (CHMS). Sci Total Environ 827: 153900. 10.1016/j.scitotenv.2022.153900.35218824
Caldwell, ASL; Middleton, LJ; Jimenez, M; Desai, R; Mcmahon, AC; Allan, CM; Handelsman, DJ; Walters, KA. (2014). Characterization of reproductive, metabolic, and endocrine features of polycystic ovary syndrome in female hyperandrogenic mouse models. Endocrinology 155: 3146–3159. 10.1210/en.2014-1196.24877633
Callan, AC; Rotander, A; Thompson, K; Heyworth, J; Mueller, JF; Odland, JØ; Hinwood, AL. (2016). Maternal exposure to perfluoroalkyl acids measured in whole blood and birth outcomes in offspring. Sci Total Environ 569-570: 1107–1113. 10.1016/j.scitotenv.2016.06.177.27387804
Cao, L; Quan, XB; Zeng, WJ; Yang, XO; Wang, MJ. (2016). Mechanism of hepatocyte apoptosis [Review]. Journal of Cell Death 9: 19–29. 10.4137/JCD.S39824.28058033
Cao, W; Liu, X; Liu, X; Zhou, Y; Zhang, X; Tian, H; Wang, J; Feng, S; Wu, Y; Bhatti, P; Wen, S; Sun, X. (2018). Perfluoroalkyl substances in umbilical cord serum and gestational and postnatal growth in a Chinese birth cohort. Environ Int 116: 197–205. 10.1016/j.envint.2018.04.015.29698896
Carlson, LA; Angrish, M; Shirke, AV; Radke, EG; Schulz, B; Kraft, A; Judson, R; Patlewicz, G; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Arzuaga, X; Davis, A; Dishaw, LV; Druwe, IL; Hollinger, H; … Thayer, KA. (2022). Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Review]. Environ Health Perspect 130: 56001. 10.1289/EHP10343.35580034
Carney, EW; Kimmel, CA. (2007). Interpretation of skeletal variations for human risk assessment: delayed ossification and wavy ribs. Birth Defects Res B Dev Reprod Toxicol 80: 473–496.18157903
Carwile, JL; Seshasayee, SM; Aris, IM; Rifas-Shiman, SL; Claus Henn, B; Calafat, AM; Sagiv, SK; Oken, E; Fleisch, AF. (2021). Prospective associations of mid-childhood plasma per- and polyfluoroalkyl substances and pubertal timing. Environ Int 156: 106729. 10.1016/j.envint.2021.106729.34171588
CDC (Centers for Disease Control and Prevention). (2022a). Biomonitoring data tables for environmental chemicals: analysis of whole blood, serum, and urine samples, NHANES 1999–2018. https://www.cdc.gov/exposurereport/data_tables.html.
CDC (Centers for Disease Control and Prevention). (2022b). National report on human exposure to environmental chemicals. Atlanta, GA: U.S. Department of Health and Human Services. https://www.cdc.gov/exposurereport/.
Chang, CJ; Barr, DB; Ryan, PB; Panuwet, P; Smarr, MM; Liu, K; Kannan, K; Yakimavets, V; Tan, Y; Ly, V; Marsit, CJ; Jones, DP; Corwin, EJ; Dunlop, AL; Liang, D. (2022). Per- and polyfluoroalkyl substance (PFAS) exposure, maternal metabolomic perturbation, and fetal growth in African American women: A meet-in-the-middle approach. Environ Int 158: 106964. 10.1016/j.envint.2021.106964.34735953
Charles, D; Berg, V; Nøst, TH; Huber, S; Sandanger, TM; Rylander, C. (2020). Pre- and post- diagnostic blood profiles of perfluoroalkyl acids in type 2 diabetes mellitus cases and controls. Environ Int 145: 106095. 10.1016/j.envint.2020.106095.32919259
Chen, H; Huang, CY; Wilson, MW; Lay, LT; Robertson, LW; Chow, CK; Glauert, HP. (1994). Effect of the peroxisome proliferators ciprofibrate and perfluorodecanoic acid on hepatic cell proliferation and toxicity in Sprague-Dawley rats. Carcinogenesis 15: 2847–2850. 10.1093/carcin/15.12.2847.8001245
Chen, L; Tong, C; Huo, X; Zhang, J; Tian, Y. (2021). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and birth outcomes: A longitudinal cohort with repeated measurements. Chemosphere 267: 128899. 10.1016/j.chemosphere.2020.128899.33220988
Chen, LC; Borges, T; Glauert, HP; Knight, SAB; Sunde, RA; Schramm, H; Oesch, F; Chow, CK; Robertson, LW. (1990). Modulation of selenium-dependent glutathione peroxidase by perfluorodecanoic acid in rats: Effect of dietary selenium. J Nutr 120: 298–304. 10.1093/jn/120.3.298.2181083
Chen, Q; Huang, R; Hua, L; Guo, Y; Huang, L; Zhao, Y; Wang, X; Zhang, J. (2018a). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and childhood atopic dermatitis: A prospective birth cohort study. Environ Health 17: 1–12. 10.1186/s12940-018-0352-7.29301538
Chen, Q; Zhang, X; Zhao, Y; Lu, W; Wu, J; Zhao, S; Zhang, J; Huang, L. (2019). Prenatal exposure to perfluorobutanesulfonic acid and childhood adiposity: A prospective birth cohort study in Shanghai, China. Chemosphere 226: 17–23. 10.1016/j.chemosphere.2019.03.095.30908964
Chen, WL; Bai, FY; Chang, YC; Chen, PC; Chen, CY. (2018b). Concentrations of perfluoroalkyl substances in foods and the dietary exposure among Taiwan general population and pregnant women. J Food Drug Anal 26: 994–1004. 10.1016/j.jfda.2017.12.011.29976417
Chen, X; Feng, X; Sun, X; Li, Y; Yang, Y; Shan, G; Zhu, L. (2022). Quantifying indirect contribution from precursors to human body burden of legacy PFASs based on paired blood and one-week duplicate diet. Environ Sci Technol 56: 5632–5640. 10.1021/acs.est.1c07465.35417148
Chinje, E; Kentish, P; Jarnot, B; George, M; Gibson, G. (1994). Induction of the CYP4A subfamily by perfluorodecanoic acid: The rat and the guinea pig as susceptible and non-susceptible species. Toxicol Lett 71: 69–75. 10.1016/0378-4274(94)90200-3.8140591
Chiu, WA; Lynch, MT; Lay, CR; Antezana, A; Malek, P; Sokolinski, S; Rogers, RD. (2022). Bayesian estimation of human population toxicokinetics of PFOA, PFOS, PFHxS, and PFNA from studies of contaminated drinking water. Environ Health Perspect 130: 127001. 10.1289/EHP10103.36454223
Christensen, JVR; Bangash, KK; Weihe, P; Grandjean, P; Nielsen, F; Jensen, TK; Petersen, MS. (2021). Maternal exposure to perfluoroalkyl chemicals and anogenital distance in the offspring: A Faroese cohort study. Reprod Toxicol 104: 52–57. 10.1016/j.reprotox.2021.06.016.34182087
Christensen, KY; Raymond, M; Meiman, J. (2019). Perfluoroalkyl substances and metabolic syndrome. Int J Hyg Environ Health 222: 147–153. 10.1016/j.ijheh.2018.08.014.30290996
Christensen, KY; Raymond, M; Thompson, BA; Anderson, HA. (2016). Perfluoroalkyl substances in older male anglers in Wisconsin. Environ Int 91: 312–318. 10.1016/j.envint.2016.03.012.27003842
Corsini, E; Sangiovanni, E; Avogadro, A; Galbiati, V; Viviani, B; Marinovich, M; Galli, CL; Dell'Agli, M; Germolec, DR. (2012). In vitro characterization of the immunotoxic potential of several perfluorinated compounds (PFCs). Toxicol Appl Pharmacol 258: 248–255. 10.1016/j.taap.2011.11.004.22119708
Corton, JC; Peters, JM; Klaunig, JE. (2018). The PPARα-dependent rodent liver tumor response is not relevant to humans: addressing misconceptions [Review]. Arch Toxicol 92: 83–119. 10.1007/s00204-017-2094-7.29197930
Craig, EA; Yan, Z; Zhao, QJ. (2015). The relationship between chemical-induced kidney weight increases and kidney histopathology in rats. J Appl Toxicol 35: 729–736. 10.1002/jat.3036.25092041
Creasy, D; Bube, A; de Rijk, E; Kandori, H; Kuwahara, M; Masson, R; Nolte, T; Reams, R; Regan, K; Rehm, S; Rogerson, P; Whitney, K. (2012). Proliferative and nonproliferative lesions of the rat and mouse male reproductive system [Review]. Toxicol Pathol 40: 40S–121S. 10.1177/0192623312454337.22949412
Creasy, DM; Chapin, RE. (2018). Chapter 17 - Male reproductive system. In Fundamentals of Toxicologic Pathology (Third Edition). London, UK: Academic Press of Elsevier. 10.1016/B978-0-12-809841-7.00017-4.
Dalsager, L; Christensen, N; Halekoh, U; Timmermann, CAG; Nielsen, F; Kyhl, HB; Husby, S; Grandjean, P; Jensen, TK; Andersen, HR. (2021a). Exposure to perfluoroalkyl substances during fetal life and hospitalization for infectious disease in childhood: A study among 1, 503 children from the Odense Child Cohort. Environ Int 149: 106395. 10.1016/j.envint.2021.106395.33508532
Dalsager, L; Christensen, N; Husby, S; Kyhl, H; Nielsen, F; Høst, A; Grandjean, P; Jensen, TK. (2016). Association between prenatal exposure to perfluorinated compounds and symptoms of infections at age 1–4years among 359 children in the Odense Child Cohort. Environ Int 96: 58–64. 10.1016/j.envint.2016.08.026.27608427
Dalsager, L; Jensen, TK; Nielsen, F; Grandjean, P; Bilenberg, N; Andersen, HR. (2021b). No association between maternal and child PFAS concentrations and repeated measures of ADHD symptoms at age 2½ and 5 years in children from the Odense Child Cohort. Teratol, Neurotoxicol 88: 107031. 10.1016/j.ntt.2021.107031.
Darrow, DC; Soule, HC; Buckman, TE. (1928). Blood volume in normal infants and children. J Clin Invest 5: 243–258. 10.1172/JCI100156.16693790
Das, KP; Wood, CR; Lin, MT; Starkov, AA; Lau, C; Wallace, KB; Corton, JC; Abbott, BD. (2017). Perfluoroalkyl acids-induced liver steatosis: Effects on genes controlling lipid homeostasis. Toxicology 378: 37–52. 10.1016/j.tox.2016.12.007.28049043
Davidson, MH. (2010). Update on CETP inhibition. 4: 394–398. 10.1016/j.jacl.2010.08.003.
Davies, B; Morris, T. (1993). Physiological parameters in laboratory animals and humans [Review]. Res, Pharm 10: 1093–1095. 10.1023/A:1018943613122.
De Boo, HA; Harding, JE. (2006). The developmental origins of adult disease (Barker) hypothesis [Review]. Aust N Z J Obstet Gynaecol 46: 4–14. 10.1111/j.1479-828X.2006.00506.x.16441686
de Simone, G; Daniels, S. R.; Kimball, TR; Roman, MJ; Romano, C; Chinali, M; Galderisi, M; Devereux, RB. (2005). Evaluation of concentric left ventricular geometry in humans - Evidence for age-related systematic underestimation. Hypertension 45: 64–68. 10.1161/01.HYP.0000150108.37527.57.15557389
Dent, MP; Carmichael, PL; Jones, KC; Martin, FL. (2015). Towards a non-animal risk assessment for anti-androgenic effects in humans [Review]. Environ Int 83: 94–106. 10.1016/j.envint.2015.06.009.26115536
Domazet, SL; Jensen, TK; Wedderkopp, N; Nielsen, F; Andersen, LB; Grøntved, A. (2020). Exposure to perfluoroalkylated substances (PFAS) in relation to fitness, physical activity, and adipokine levels in childhood: The European youth heart study. Environ Res 191: 110110. 10.1016/j.envres.2020.110110.32871146
Dong, GH; Tung, KY; Tsai, CH; Liu, MM; Wang, D; Liu, W; Jin, YH; Hsieh, WS; Lee, YL; Chen, PC. (2013). Serum polyfluoroalkyl concentrations, asthma outcomes, and immunological markers in a case-control study of Taiwanese children. Environ Health Perspect 121: 507–513, 513e501–508. 10.1289/ehp.1205351.23309686
Dong, Z; Wang, H; Yu, YY; Li, YB; Naidu, R; Liu, Y. (2019). Using 2003–2014 U.S. NHANES data to determine the associations between per- and polyfluoroalkyl substances and cholesterol: Trend and implications. Ecotoxicol Environ Saf 173: 461–468. 10.1016/j.ecoenv.2019.02.061.30798190
Duan, Y; Sun, H; Yao, Y; Meng, Y; Li, Y. (2020). Distribution of novel and legacy per-/polyfluoroalkyl substances in serum and its associations with two glycemic biomarkers among Chinese adult men and women with normal blood glucose levels. Environ Int 134: 105295. 10.1016/j.envint.2019.105295.31726357
Dunder, L; Lind, PM; Salihovic, S; Stubleski, J; Kärrman, A; Lind, L. (2022). Changes in plasma levels of per- and polyfluoroalkyl substances (PFAS) are associated with changes in plasma lipids - A longitudinal study over 10 years. Environ Res 211: 112903. 10.1016/j.envres.2022.112903.35231461
Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Gibbs, ST; Granville, CA; Blystone, CR. (2019). Toxicokinetics of perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA) and perfluorodecanoic acid (PFDA) in male and female Hsd:Sprague dawley SD rats following intravenous or gavage administration. Xenobiotica 50: 1–11. 10.1080/00498254.2019.1683776.31625424
Dzierlenga, M, .W.;; Crawford, L, .; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Eick, SM; Demicco, E; Valeri, L; Woodruff, TJ; Morello-Frosch, R; Hom Thepaksorn, EK; Izano, MA; Cushing, LJ; Wang, Y; Smith, SC; Gao, S; Park, JS; Padula, AM. (2020). Associations between prenatal maternal exposure to per- and polyfluoroalkyl substances (PFAS) and polybrominated diphenyl ethers (PBDEs) and birth outcomes among pregnant women in San Francisco. Environ Health 19: 100–100. 10.1186/s12940-020-00654-2.32938446
EMEA (European Medicines Agency). (2008). Non-clinical guideline on drug induced hepatotoxicity. (EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003355.pdf.
Ernst, A; Brix, N; Lauridsen, LLB; Olsen, J; Parner, ET; Liew, Z; Olsen, LH; Ramlau-Hansen, CH. (2019). Exposure to perfluoroalkyl substances during fetal life and pubertal development in boys and girls from the Danish National Birth Cohort. Environ Health Perspect 127: 17004. 10.1289/EHP3567.30628845
Evans, H; Killoran, KE; Mitre, E. (2014). Measuring Local Anaphylaxis in Mice. J Vis Exp 14: e52005. 10.3791/52005.
Evans, TJ; Ganjam, VK. (2011). Chapter 2 - Reproductive anatomy and physiology. In Gupta, RC (Ed.), Reproductive and Developmental Toxicology (1st ed., pp. 7–32). San Diego, CA: Academic Press. 10.1016/B978-0-12-382032-7.10002-5.
Fàbrega, F; Kumar, V; Benfenati, E; Schuhmacher, M; Domingo, JL; Nadal, M. (2015). Physiologically based pharmacokinetic modeling of perfluoroalkyl substances in the human body. Toxicol Environ Chem 97: 814–827. 10.1080/02772248.2015.1060976.
Feghali, M; Venkataramanan, R; Caritis, S. (2015). Pharmacokinetics of drugs in pregnancy. Semin Perinatol 39: 512–519. 10.1053/j.semperi.2015.08.003.26452316
Fleisch, AF; Rifas-Shiman, SL; Mora, AM; Calafat, AM; Ye, X; Luttmann-Gibson, H; Gillman, MW; Oken, E; Sagiv, SK. (2017). Early-life exposure to perfluoroalkyl substances and childhood metabolic function. Environ Health Perspect 125: 481–487. 10.1289/EHP303.27586368
Foster, P; Gray, LE Jr. (2013). Toxic responses of the reproductive system. In Klaassen CD (Ed.), Casarett & Doull's toxicology: The basic science of poisons (8th ed., pp. 861–906). New York, NY: McGraw-Hill Education. https://www.mheducation.com/highered/product/casarett-doull-s-toxicology-basic-science-poisons-9th-edition-klaassen/9781259863745.html.
Fraser, AJ; Webster, TF; Watkins, DJ; Strynar, MJ; Kato, K; Calafat, AM; Vieira, VM; Mcclean, MD. (2013). Polyfluorinated compounds in dust from homes, offices, and vehicles as predictors of concentrations in office workers' serum. Environ Int 60: 128–136. 10.1016/j.envint.2013.08.012.24041736
Frawley, RP; Smith, M; Cesta, MF; Hayes-Bouknight, S; Blystone, C; Kissling, GE; Harris, S; Germolec, D. (2018). Immunotoxic and hepatotoxic effects of perfluoro-n-decanoic acid (PFDA) on female Harlan Sprague-Dawley rats and B6C3F1/N mice when administered by oral gavage for 28 days. J Immunotoxicol 15: 41–52. 10.1080/1547691X.2018.1445145.29514525
Friis-Hansen, B. (1961). Body water compartments in children: Changes during growth and related changes in body composition. Pediatrics 28: 169–181.13702099
Fu, Y; Wang, T; Fu, Q; Wang, P; Lu, Y. (2014). Associations between serum concentrations of perfluoroalkyl acids and serum lipid levels in a Chinese population. Ecotoxicol Environ Saf 106: 246–252. 10.1016/j.ecoenv.2014.04.039.24863755
Fujii, Y; Niisoe, T; Harada, KH; Uemoto, S; Ogura, Y; Takenaka, K; Koizumi, A. (2015). Toxicokinetics of perfluoroalkyl carboxylic acids with different carbon chain lengths in mice and humans. J Occup Health 57: 1–12. 10.1539/joh.14-0136-OA.25422127
Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. (1993). The immunological basis for immunization module 2 : Diphtheria. (WHO/EPI/Gen/93.11–18).
Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. http://apps.who.int/iris/bitstream/handle/10665/58891/WHO-EPI-GEN-93.12-mod2-eng.pdf?sequence=38&isAllowed=y.
Gao, K, e; Zhuang, T; Liu, X; Fu, J; Zhang, J; Fu, J, ie; Wang, L; Zhang, A; Liang, Y; Song, M; Jiang, G. (2019). Prenatal Exposure to Per- and Polyfluoroalkyl Substances (PFASs) and Association between the Placental Transfer Efficiencies and Dissociation Constant of Serum Proteins-PFAS Complexes. Environ Sci Technol 53: 6529–6538. 10.1021/acs.est.9b00715.31099564
Gao, Y; Luo, J; Zhang, Y; Pan, C; Ren, Y; Zhang, J; Tian, Y; Cohort, SB. (2022). Prenatal Exposure to Per- and Polyfluoroalkyl Substances and Child Growth Trajectories in the First Two Years. Environ Health Perspect 130: 37006. 10.1289/EHP9875.35285689
Gardener, H; Sun, Q; Grandjean, P. (2021). PFAS concentration during pregnancy in relation to cardiometabolic health and birth outcomes. Environ Res 192: 110287. 10.1016/j.envres.2020.110287.33038367
Gebbink, WA; Berger, U; Cousins, IT. (2015). Estimating human exposure to PFOS isomers and PFCA homologues: the relative importance of direct and indirect (precursor) exposure. Environ Int 74: 160–169. 10.1016/j.envint.2014.10.013.25454233
Getz, GS; Reardon, CA. (2012). Animal models of atherosclerosis [Review]. Arterioscler Thromb Vasc Biol 32: 1104–1115. 10.1161/ATVBAHA.111.237693.22383700
Glauert, HP; Srinivasan, S; Tatum, VL; Chen, LC; Saxon, DM; Lay, LT; Borges, T; Baker, M; Chen, LH; Robertson, LW; Chow, CK. (1992). Effects of the peroxisome proliferators ciprofibrate and perfluorodecanoic acid on hepatic cellular antioxidants and lipid peroxidation in rats. Pharmacol, Biochem 43: 1353–1359. 10.1016/0006-2952(92)90513-I.
Glynn, A; Kotova, N; Dahlgren, E; Lindh, C; Jakobsson, K; Gyllenhammar, I; Lignell, S; Nälsén, C. (2020). Determinants of serum concentrations of perfluoroalkyl acids (PFAAs) in school children and the contribution of low-level PFAA-contaminated drinking water. Environ Sci Process Impacts 22: 930–944. 10.1039/c9em00497a.32040098
Godin, CS; Myhr, BC; Lawlor, TE; Young, RR; Murli, H; Cifone, MA. (1992). Assessment of the potential genotoxicity of perfluorodecanoic acid and chlorotrifluoroethylene trimer and tetramer acids. Fundam Appl Toxicol 18: 557–569. 10.1016/0272-0590(92)90115-X.1526368
Goecke-Flora, CM; Wyman, JF; Jarnot, BM; Reo, NV. (1995). Effect of the peroxisome proliferator perfluoro-n-decanoic acid on glucose transport in the isolated perfused rat liver. Chem Res Toxicol 8: 77–81. 10.1021/tx00043a010.7703370
Goeden, HM; Greene, CW; Jacobus, JA. (2019). A transgenerational toxicokinetic model and its use in derivation of Minnesota PFOA water guidance. J Expo Sci Environ Epidemiol 29: 183–195. 10.1038/s41370-018-0110-5.30631142
Goldman, JM; Murr, AS; Cooper, RL. (2007). The rodent estrous cycle: Characterization of vaginal cytology and its utility in toxicological studies [Review]. Birth Defects Res B Dev Reprod Toxicol 80: 84–97. 10.1002/bdrb.20106.17342777
Goodrich, JA; Alderete, TL; Baumert, BO; Berhane, K; Chen, Z; Gilliland, FD; Goran, MI; Hu, X; Jones, DP; Margetaki, K; Rock, S; Stratakis, N; Valvi, D; Walker, DI; Conti, DV; Chatzi, L. (2021). Exposure to Perfluoroalkyl Substances and Glucose Homeostasis in Youth. Environ Health Perspect 129: 97002. 10.1289/EHP9200.34468161
Goudarzi, H; Miyashita, C; Okada, E; Kashino, I; Chen, CJ; Ito, S; Araki, A; Kobayashi, S; Matsuura, H; Kishi, R. (2017). Prenatal exposure to perfluoroalkyl acids and prevalence of infectious diseases up to 4 years of age. Environ Int 104: 132–138. 10.1016/j.envint.2017.01.024.28392064
Goudarzi, H; Miyashita, C; Okada, E; Kashino, I; Kobayashi, S; Chen, CJ; Ito, S; Araki, A; Matsuura, H; Ito, YM; Kishi, R. (2016). Effects of prenatal exposure to perfluoroalkyl acids on prevalence of allergic diseases among 4-year-old children. Environ Int 94: 124–132. 10.1016/j.envint.2016.05.020.27236407
Grandjean, P; Andersen, EW; Budtz-Jørgensen, E; Nielsen, F; Mølbak, K; Weihe, P; Heilmann, C. (2012). Serum vaccine antibody concentrations in children exposed to perfluorinated compounds. JAMA 307: 391–397. 10.1001/jama.2011.2034.22274686
Grandjean, P; Bateson, T. (2021). RE: Benchmark analysis for PFAS immunotoxicity. Available online at (accessed
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Budtz-Jørgensen, E. (2017a). Serum vaccine antibody concentrations in adolescents exposed to perfluorinated compounds. Environ Health Perspect 125: 077018. 10.1289/EHP275.28749778
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Timmermann, A; Budtz-Jørgensen, E. (2017b). Estimated exposures to perfluorinated compounds in infancy predict attenuated vaccine antibody concentrations at age 5-years. J Immunotoxicol 14: 188–195. 10.1080/1547691X.2017.1360968.28805477
Grandjean, P; Timmermann, CAG; Kruse, M; Nielsen, F; Vinholt, PJ; Boding, L; Heilmann, C; Mølbak, K. (2020). Severity of COVID-19 at elevated exposure to perfluorinated alkylates. PLoS ONE 15: e0244815. 10.1371/journal.pone.0244815.33382826
Gump, BB; Wu, Q; Dumas, AK; Kannan, K. (2011). Perfluorochemical (PFC) exposure in children: Associations with impaired response inhibition. Environ Sci Technol 45: 8151–8159. 10.1021/es103712g.21682250
Guo, J; Zhang, J; Wang, Z; Zhang, L; Qi, X; Zhang, Y; Chang, X; Wu, C; Zhou, Z. (2021). Umbilical cord serum perfluoroalkyl substance mixtures in relation to thyroid function of newborns: Findings from Sheyang Mini Birth Cohort Study. Chemosphere 273: 129664. 10.1016/j.chemosphere.2021.129664.33493812
Gutshall, DM; Pilcher, GD; Langley, AE. (1988). Effect of thyroxine supplementation on the response to perfluoro-n-decanoic acid (PFDA) in rats. J Toxicol Environ Health 24: 491–498. 10.1080/15287398809531179.3411633
Gutshall, DM; Pilcher, GD; Langley, AE. (1989). Mechanism of the serum thyroid hormone lowering effect of perfluoro-n-decanoic acid (PFDA) in rats. J Toxicol Environ Health 28: 53–65. 10.1080/15287398909531328.2506363
Guyatt, G; Oxman, AD; Akl, EA; Kunz, R; Vist, G; Brozek, J; Norris, S; Falck-Ytter, Y; Glasziou, P; DeBeer, H; Jaeschke, R; Rind, D; Meerpohl, J; Dahm, P; Schünemann, HJ. (2011). GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol 64: 383–394. 10.1016/j.jclinepi.2010.04.026.21195583
Gyllenhammar, I; Diderholm, B; Gustafsson, J; Berger, U; Ridefelt, P; Benskin, JP; Lignell, S; Lampa, E; Glynn, A. (2018). Perfluoroalkyl acid levels in first-time mothers in relation to offspring weight gain and growth. Environ Int 111: 191–199. 10.1016/j.envint.2017.12.002.29223808
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: A review of adaptive (adverse and non-adverse) changes—Conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hall, SM; Zhang, S; Hoffman, K; Miranda, ML; Stapleton, HM. (2022). Concentrations of per- and polyfluoroalkyl substances (PFAS) in human placental tissues and associations with birth outcomes. Chemosphere 295: 133873. 10.1016/j.chemosphere.2022.133873.35143854
Hallberg, L; Högdahl, AM; Nilsson, L; Rybo, G. (1966). Menstrual blood loss--a population study. Variation at different ages and attempts to define normality. Acta Obstet Gynecol Scand 45: 320–351. 10.3109/00016346609158455.5922481
Han, W; Gao, Y; Yao, Q; Yuan, T; Wang, Y; Zhao, S; Shi, R; Bonefeld-Jorgensen, EC; Shen, X; Tian, Y. (2018). Perfluoroalkyl and polyfluoroalkyl substances in matched parental and cord serum in Shandong, China. Environ Int 116: 206–213. 10.1016/j.envint.2018.04.025.29698897
Harada, K; Inoue, K; Morikawa, A; Yoshinaga, T; Saito, N; Koizumi, A. (2005). Renal clearance of perfluorooctane sulfonate and perfluorooctanoate in humans and their species-specific excretion. Environ Res 99: 253–261. 10.1016/j.envres.2004.12.003.16194675
Harbison, RD; Bourgeois, MM; Johnson, GT. (2015). Hamilton & Hardy’s industrial toxicology (6th ed.). Hoboken, NJ: John Wiley & Sons, Inc. http://www.wiley.com/WileyCDA/WileyTitle/productCd-0470929731,subjectCd-CH50.html.
Hardell, E; Kärrman, A; van Bavel, B; Bao, J; Carlberg, M; Hardell, L. (2014). Case-control study on perfluorinated alkyl acids (PFAAs) and the risk of prostate cancer. Environ Int 63: 35–39. 10.1016/j.envint.2013.10.005.24246240
Harris, MH; Oken, E; Rifas-Shiman, SL; Calafat, AM; Bellinger, DC; Webster, TF; White, RF; Sagiv, SK. (2021). Prenatal and childhood exposure to per- and polyfluoroalkyl substances (PFAS) and child executive function and behavioral problems. Environ Res 202: 111621. 10.1016/j.envres.2021.111621.34237332
Harris, MH; Oken, E; Rifas-Shiman, SL; Calafat, AM; Ye, X; Bellinger, DC; Webster, TF; White, RF; Sagiv, SK. (2018). Prenatal and childhood exposure to per- and polyfluoroalkyl substances (PFASs) and child cognition. Environ Int 115: 358–369. 10.1016/j.envint.2018.03.025.29705692
Harris, MH; Rifas-Shiman, SL; Calafat, AM; Ye, X; Mora, AM; Webster, TF; Oken, E; Sagiv, SK. (2017). Predictors of per- and polyfluoroalkyl substance (PFAS) plasma concentrations in 6–10 year old American children. Environ Sci Technol 51: 5193–5204. 10.1021/acs.est.6b05811.28325044
Harris, MW; Birnbaum, LS. (1989). Developmental toxicity of perfluorodecanoic acid in C57BL/6N mice. Fundam Appl Toxicol 12: 442–448. 10.1016/0272-0590(89)90018-3.2731659
Harris, MW; Uraih, LC; Birnbaum, LS. (1989). Acute toxicity of perfluorodecanoic acid in C57BL/6 mice differs from 2, 3, 7, 8-tetrachlorodibenzo-p-dioxin. Fundam Appl Toxicol 13: 723–736. 10.1016/0272-0590(89)90330-8.2620793
Harrison, EH; Lane, JS; Luking, S; Van Rafelghem, MJ; Andersen, ME. (1988). Perfluoro-n-decanoic acid: Induction of peroxisomal beta-oxidation by a fatty acid with dioxin-like toxicity. Lipids 23: 115–119. 10.1007/BF02535290.3367697
Hashem, MS; Kalashyan, H; Choy, J; Chiew, SK; Shawki, AH; Dawood, AH; Becher, H. (2015). Left ventricular relative wall thickness versus left ventricular mass index in non-cardioembolic stroke patients. Medicine (Baltimore) 94: e872. 10.1097/MD.0000000000000872.25997067
Heo, JJ; Lee, JW; Kim, SK; Oh, JE. (2014). Foodstuff analyses show that seafood and water are major perfluoroalkyl acids (PFAAs) sources to humans in Korea. J Hazard Mater 279: 402–409. 10.1016/j.jhazmat.2014.07.004.25093550
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hjermitslev, MH; Long, M; Wielsøe, M; Bonefeld-Jørgensen, EC. (2020). Persistent organic pollutants in Greenlandic pregnant women and indices of foetal growth: The ACCEPT study. Sci Total Environ 698: 134118. 10.1016/j.scitotenv.2019.134118.31494415
Holder, C; Deluca, N; Luh, J; Alexander, P; Minucci, JM; Vallero, DA; Thomas, K; Cohen Hubal, EA. (2023). Systematic evidence mapping of potential exposure pathways for per- and polyfluoroalkyl substances based on measured occurrence in multiple media [Review]. Environ Sci Technol 57: 5107–5116. 10.1021/acs.est.2c07185.36940151
Hotchkiss, AK; Rider, CV; Blystone, CR; Wilson, VS; Hartig, PC; Ankley, GT; Foster, PM; Gray, CL; Gray, LE. (2008). Fifteen years after &quot;Wingspread&quot;--environmental endocrine disrupters and human and wildlife health: where we are today and where we need to go [Review]. Toxicol Sci 105: 235–259. 10.1093/toxsci/kfn030.18281716
Høyer, BB; Bonde, JP; Tøttenborg, SS; Ramlau-Hansen, CH; Lindh, C; Pedersen, HS; Toft, G. (2017). Exposure to perfluoroalkyl substances during pregnancy and child behaviour at 5 to 9 years of age. Horm Behav 101: 105–112. 10.1016/j.yhbeh.2017.11.007.29133180
Huang, M; Jiao, J; Zhuang, P; Chen, X; Wang, J; Zhang, Y. (2018). Serum polyfluoroalkyl chemicals are associated with risk of cardiovascular diseases in national US population. Environ Int 119: 37–46. 10.1016/j.envint.2018.05.051.29933236
Huang, Q; Liu, L; Wu, Y; Wang, X; Luo, L; Nan, B; Zhang, J; Tian, M; Shen, H. (2019a). Seminal plasma metabolites mediate the associations of multiple environmental pollutants with semen quality in Chinese men. Environ Int 132: 105066. 10.1016/j.envint.2019.105066.31394396
Huang, R; Chen, Q; Zhang, L; Luo, K; Chen, L; Zhao, S; Feng, L; Zhang, J. (2019b). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and the risk of hypertensive disorders of pregnancy. Environ Health 18: 5. 10.1186/s12940-018-0445-3.30626391
Huo, X; Zhang, L; Huang, R; Feng, L; Wang, W; Zhang, J; Cohort, SB. (2020). Perfluoroalkyl substances exposure in early pregnancy and preterm birth in singleton pregnancies: a prospective cohort study. Environ Health 19: 60. 10.1186/s12940-020-00616-8.32493312
ICH Expert Working Group. (2005). Immunotoxicity studies for human pharmaceuticals S8 11. In ICH Harmonised Tripartite Guideline.
Inoue, K; Ritz, B; Andersen, SL; Ramlau-Hansen, CH; Høyer, BB; Bech, BH; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J; Liew, Z. (2019). Perfluoroalkyl substances and maternal thyroid hormones in early pregnancy; findings in the Danish National Birth Cohort. Environ Health Perspect 127: 117002. 10.1289/EHP5482.31714155
IPCS (International Programme on Chemical Safety). (1996). Principles and methods for assessing direct immunotoxicity associated with exposure to chemicals. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc180.htm.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
IQEHC (Institute for Quality and Efficiency in Health Care). (2014). Deciding whether or not to treat subclinical hypothyroidism. https://www.informedhealth.org/underactive-thyroid-hypothyroidism.2713.en.pdf?all_backgrounds=0&all_details=0&all_lexicons=0&all_reports=0&overview=1&print=1&theme=0.
Ishibashi, H; Hirano, M; Kim, EY; Iwata, H. (2019). In vitro and in silico evaluations of binding affinities of perfluoroalkyl substances to baikal seal and human peroxisome proliferator-activated receptor α. Environ Sci Technol 53: 2181–2188. 10.1021/acs.est.8b07273.30649875
Itoh, S; Araki, A; Miyashita, C; Yamazaki, K; Goudarzi, H; Minatoya, M; Ait Bamai, Y; Kobayashi, S; Okada, E; Kashino, I; Yuasa, M; Baba, T; Kishi, R. (2019). Association between perfluoroalkyl substance exposure and thyroid hormone/thyroid antibody levels in maternal and cord blood: The Hokkaido Study. Environ Int 133: 105139. 10.1016/j.envint.2019.105139.31518930
Jaeschke, H; Lemasters, JJ. (2003). Apoptosis versus oncotic necrosis in hepatic ischemia/reperfusion injury. Gastroenterology 125: 1246–1257. 10.1016/S0016-5085(03)01209-5.14517806
Jain, RB. (2019). Synergistic impact of co-exposures to toxic metals cadmium, lead, and mercury along with perfluoroalkyl substances on the healthy kidney function. Environ Res 169: 342–347. 10.1016/j.envres.2018.11.037.30504076
Jain, RB. (2020a). Impact of the co-occurrence of obesity with diabetes, anemia, hypertension, and albuminuria on concentrations of selected perfluoroalkyl acids. Environ Pollut 266 Pt. 2: 115207. 10.1016/j.envpol.2020.115207.32698119
Jain, RB. (2020b). Variabilities in concentrations of selected perfluoroalkyl acids among normotensives and hypertensives across various stages of glomerular function. Arch Environ Occup Health 76: 1–11. 10.1080/19338244.2020.1732856.32048551
Jain, RB. (2021). Perfluoroalkyl acids and their isomers, diabetes, anemia, and albuminuria: Variabilities with deteriorating kidney function. Ecotoxicol Environ Saf 208: 111625. 10.1016/j.ecoenv.2020.111625.33396145
Jain, RB; Ducatman, A. (2019a). Roles of gender and obesity in defining correlations between perfluoroalkyl substances and lipid/lipoproteins. Sci Total Environ 653: 74–81. 10.1016/j.scitotenv.2018.10.362.30408670
Jain, RB; Ducatman, A. (2019b). Selective associations of recent low concentrations of perfluoroalkyl substances with liver function biomarkers: nhanes 2011 to 2014 data on us adults aged ≥20 years. J Occup Environ Med 61: 293–302. 10.1097/JOM.0000000000001532.30589657
Janis, JA; Rifas-Shiman, SL; Seshasayee, SM; Sagiv, S; Calafat, AM; Gold, DR; Coull, BA; Rosen, CJ; Oken, E; Fleisch, AF. (2021). Plasma concentrations of per- and polyfluoroalkyl substances and body composition from mid-childhood to early adolescence. J Clin Endocrinol Metab 106: e3760–e3770. 10.1210/clinem/dgab187.33740056
Je, I, −G; Kim, D, uk-Sil, Kim, S, −W; Lee, S; Lee, HS; Park, E, −K; Khang, D; Kim, SH. (2015). Tyrosol suppresses allergic inflammation by inhibiting the activation of phosphoinositide 3-kinase in mast cells. PLoS ONE 10: e0129829. 10.1371/journal.pone.0129829.26068872
Jensen, RC; Andersen, MS; Larsen, PV; Glintborg, D; Dalgård, C; Timmermann, CAG; Nielsen, F; Sandberg, MB; Andersen, HR; Christesen, HT; Grandjean, P; Jensen, TK. (2020a). Prenatal Exposures to Perfluoroalkyl Acids and Associations with Markers of Adiposity and Plasma Lipids in Infancy: An Odense Child Cohort Study. Environ Health Perspect 128: 77001. 10.1289/EHP5184.32628516
Jensen, RC; Glintborg, D; Gade Timmermann, CA; Nielsen, F; Kyhl, HB; Frederiksen, H; Andersson, AM; Juul, A; Sidelmann, JJ; Andersen, HR; Grandjean, P; Andersen, MS; Jensen, TK. (2020b). Prenatal exposure to perfluorodecanoic acid is associated with lower circulating concentration of adrenal steroid metabolites during mini puberty in human female infants. The odense child cohort. Environ Res 182: 109101. 10.1016/j.envres.2019.109101.32069767
Jensen, RC; Glintborg, D; Timmermann, CAG; Nielsen, F; Kyhl, HB; Andersen, HR; Grandjean, P; Jensen, TK; Andersen, M. (2018). Perfluoroalkyl substances and glycemic status in pregnant Danish women: The Odense Child Cohort. Environ Int 116: 101–107. 10.1016/j.envint.2018.04.010.29660612
Jensen, TK; Andersen, LB; Kyhl, HB; Nielsen, F; Christesen, HT; Grandjean, P. (2015). Association between perfluorinated compound exposure and miscarriage in Danish pregnant women. PLoS ONE 10: e0123496. 10.1371/journal.pone.0123496.25848775
Ji, K; Kim, S; Kho, Y; Paek, D; Sakong, J; Ha, J; Kim, S; Choi, K. (2012). Serum concentrations of major perfluorinated compounds among the general population in Korea: dietary sources and potential impact on thyroid hormones. Environ Int 45: 78–85. 10.1016/j.envint.2012.03.007.22580293
Jiang, W; Zhang, Y; Zhu, L; Deng, J. (2014). Serum levels of perfluoroalkyl acids (PFAAs) with isomer analysis and their associations with medical parameters in Chinese pregnant women. Int, Environ 64: 40–47. 10.1016/j.envint.2013.12.001.
Jin, H; Zhang, Y; Jiang, W; Zhu, L; Martin, JW. (2016). Isomer-Specific Distribution of Perfluoroalkyl Substances in Blood. Environ Sci Technol 50: 7808–7815. 10.1021/acs.est.6b01698.27295125
Joensen, UN; Veyrand, B; Antignac, JP; Blomberg Jensen, M; Petersen, JH; Marchand, P; Skakkebæk, NE; Andersson, AM; Le Bizec, B; Jørgensen, N. (2013). PFOS (perfluorooctanesulfonate) in serum is negatively associated with testosterone levels, but not with semen quality, in healthy men. Hum Reprod 28: 599–608. 10.1093/humrep/des425.23250927
Jones, MEE; Boon, WC; Proietto, J; Simpson, ER. (2006). Of mice and men: The evolving phenotype of aromatase deficiency [Review]. Trends Endocrinol Metab 17: 55–64. 10.1016/j.tem.2006.01.004.16480891
Joshi-Barve, S; Kirpich, I; Cave, MC; Marsano, LS; McClain, CJ. (2015). Alcoholic, nonalcoholic, and toxicant-associated steatohepatitis: Mechanistic similarities and differences [Review]. CMGH 1: 356–367. 10.1016/j.jcmgh.2015.05.006.28210688
Kadel, S; Kovats, S. (2018). Sex Hormones Regulate Innate Immune Cells and Promote Sex Differences in Respiratory Virus Infection [Review]. Front Immunol 9: 1653. 10.3389/fimmu.2018.01653.30079065
Kang, H; Lee, HK; Moon, HB; Kim, S; Lee, J; Ha, M; Hong, S; Kim, S; Choi, K. (2018). Perfluoroalkyl acids in serum of Korean children: Occurrences, related sources, and associated health outcomes. Sci Total Environ 645: 958–965. 10.1016/j.scitotenv.2018.07.177.30032090
Karásková, P; Venier, M; Melymuk, L; Bečanová, J; Vojta, Š; Prokeš, R; Diamond, ML; Klánová, J. (2016). Perfluorinated alkyl substances (PFASs) in household dust in Central Europe and North America. Environ Int 94: 315–324. 10.1016/j.envint.2016.05.031.27295048
Karlsen, M; Grandjean, P; Weihe, P; Steuerwald, U; Oulhote, Y; Valvi, D. (2017). Early-life exposures to persistent organic pollutants in relation to overweight in preschool children. Reprod Toxicol 68: 145–153. 10.1016/j.reprotox.2016.08.002.27496715
Kashino, I; Sasaki, S; Okada, E; Matsuura, H; Goudarzi, H; Miyashita, C; Okada, E; Ito, YM; Araki, A; Kishi, R. (2020). Prenatal exposure to 11 perfluoroalkyl substances and fetal growth: A large-scale, prospective birth cohort study. Environ Int 136: 105355. 10.1016/j.envint.2019.105355.32029284
Kass, GEN. (2006). Mitochondrial involvement in drug-induced hepatic injury. Chem Biol Interact 163: 145–159. 10.1016/j.cbi.2006.06.007.16889760
Kawabata, K; Matsuzaki, H; Nukui, S; Okazaki, M; Sakai, A; Kawashima, Y; Kudo, N. (2017). Perfluorododecanoic acid induces cognitive deficit in adult rats. Toxicol Sci 157: 421–428. 10.1093/toxsci/kfx058.28402547
Kawashima, Y; Kobayashi, H; Miura, H; Kozuka, H. (1995). Characterization of hepatic responses of rat to administration of perfluorooctanoic and perfluorodecanoic acids at low levels. Toxicology 99: 169–178. 10.1016/0300-483X(95)03027-D.7610463
Kelling, CK; Van Rafelghem, MJ; Menahan, LA; Peterson, RE. (1987). Effects of perfluorodecanoic acid on hepatic indices of thyroid status in the rat. Biochem Pharmacol 36: 1337–1344. 10.1016/0006-2952(87)90091-8.3593420
Khalil, N; Ducatman, AM; Sinari, S; Billheimer, D; Hu, C; Littau, S; Burgess, JL. (2020). Per- and polyfluoroalkyl substance and cardio metabolic markers in firefighters. J Occup Environ Med 62: 1076–1081. 10.1097/JOM.0000000000002062.33105404
Kielsen, K; Shamim, Z; Ryder, LP; Nielsen, F; Grandjean, P; Budtz-Jørgensen, E; Heilmann, C. (2016). Antibody response to booster vaccination with tetanus and diphtheria in adults exposed to perfluorinated alkylates. J Immunotoxicol 13: 270–273. 10.3109/1547691X.2015.1067259.26181512
Kim, HY; Kim, KN; Shin, CH; Lim, YH; Kim, JI; Kim, BN; Hong, YC; Lee, YA. (2020a). The relationship between perfluoroalkyl substances concentrations and thyroid function in early childhood: A prospective cohort study. Thyroid 30: 1556–1565. 10.1089/thy.2019.0436.32368952
Kim, K; Bennett, DH; Calafat, AM; Hertz-Picciotto, I; Shin, HM. (2020b). Temporal trends and determinants of serum concentrations of per- and polyfluoroalkyl substances among Northern California mothers with a young child, 2009-2016. Environ Res 186: 109491. 10.1016/j.envres.2020.109491.32361076
Kim, OJ; Kim, S; Park, EY; Oh, JK; Jung, SK; Park, S; Hong, S; Jeon, HL; Kim, HJ; Park, B; Park, B; Kim, S; Kim, B. (2023). Exposure to serum perfluoroalkyl substances and biomarkers of liver function: The Korean national environmental health survey 2015-2017. Chemosphere 322: 138208. 10.1016/j.chemosphere.2023.138208.36822523
Kim, S; Choi, K; Ji, K; Seo, J; Kho, Y; Park, J; Kim, S; Park, S; Hwang, I; Jeon, J; Yang, H; Giesy, JP. (2011). Trans-placental transfer of thirteen perfluorinated compounds and relations with fetal thyroid hormones. Environ Sci Technol 45: 7465–7472. 10.1021/es202408a.21805959
Kim, SC; Hong, JT; Jang, SJ; Kang, WS; Yoo, HS; Yun, YP. (1998). Formation of 8-oxodeoxyguanosine in liver DNA and hepatic injury by peroxisome proliferator clofibrate and perfluorodecanoic acid in rats. J Toxicol Sci 23: 113–119. 10.2131/jts.23.2_113.9644651
Kim, SJ; Choi, EJ; Choi, GW; Lee, YB; Cho, HY. (2019). Exploring sex differences in human health risk assessment for PFNA and PFDA using a PBPK model. Arch Toxicol 93: 311–330. 10.1007/s00204-018-2365-y.30483840
Kim, SK; Kannan, K. (2007). Perfluorinated acids in air, rain, snow, surface runoff, and lakes: Relative importance of pathways to contamination of urban lakes. Environ Sci Technol 41: 8328–8334. 10.1021/es072107t.18200859
Kim, YR; White, N; Bräunig, J; Vijayasarathy, S; Mueller, JF; Knox, CL; Harden, FA; Pacella, R; Toms, LL. (2020c). Per- and poly-fluoroalkyl substances (PFASs) in follicular fluid from women experiencing infertility in Australia. Environ Res 190: 109963. 10.1016/j.envres.2020.109963.32745751
Kjeldsen, LS; Bonefeld-Jørgensen, EC. (2013). Perfluorinated compounds affect the function of sex hormone receptors. Environ Sci Pollut Res Int 20: 8031–8044. 10.1007/s11356-013-1753-3.23764977
Klein, SL; Flanagan, KL. (2016). Sex differences in immune responses [Review]. Nat Rev Immunol 16: 626–638. 10.1038/nri.2016.90.27546235
Kleiner, DE; Weerasinghe, P; Buja, LM. (2012). Oncosis: An important non-apoptotic mode of cell death. Exp Mol Pathol 93: 302–308. 10.1016/j.yexmp.2012.09.018.23036471
Knobeloch, L; Imm, P; Anderson, H. (2012). Perfluoroalkyl chemicals in vacuum cleaner dust from 39 Wisconsin homes. Chemosphere 88: 779–783. 10.1016/j.chemosphere.2012.03.082.22542201
Konwick, BJ; Tomy, GT; Ismail, N; Peterson, JT; Fauver, RJ; Higginbotham, D; Fisk, AT. (2008). Concentrations, USA surface waters near and distant to a major use source. Environ Toxicol Chem 27: 2011–2018. 10.1897/07-659.1.18419175
Koponen, J; Winkens, K; Airaksinen, R; Berger, U; Vestergren, R; Cousins, IT; Karvonen, AM; Pekkanen, J; Kiviranta, H. (2018). Longitudinal trends of per- and polyfluoroalkyl substances in children's serum. Environ Int 121: 591–599. 10.1016/j.envint.2018.09.006.30308470
Koshy, TT; Attina, TM; Ghassabian, A; Gilbert, J; Burdine, LK; Marmor, M; Honda, M; Chu, DB; Han, X; Shao, Y; Kannan, K; Urbina, EM; Trasande, L. (2017). Serum perfluoroalkyl substances and cardiometabolic consequences in adolescents exposed to the World Trade Center disaster and a matched comparison group. Environ Int 109: 128–135. 10.1016/j.envint.2017.08.003.28890218
Kotthoff, M; Müller, J; Jürling, H; Schlummer, M; Fiedler, D. (2015). Perfluoroalkyl and polyfluoroalkyl substances in consumer products. Environ Sci Pollut Res Int 22: 14546–14559. 10.1007/s11356-015-4202-7.25854201
Kudo, N. (2015). Metabolism and pharmacokinetics. In DeWitt JC (Ed.), Toxicological Effects of Perfluoroalkyl and Polyfluoroalkyl Substances (pp. 151–175). New York, NY: Springer International Publishing. 10.1007/978-3-319-15518-0_6.
Kudo, N; Kawashima, Y. (2003). Induction of triglyceride accumulation in the liver of rats by perfluorinated fatty acids with different carbon chain lengths: Comparison with induction of peroxisomal beta-oxidation. Biol Pharm Bull 26: 47–51. 10.1248/bpb.26.47.12520171
Kudo, N; Suzuki, E; Katakura, M; Ohmori, K; Noshiro, R; Kawashima, Y. (2001). Comparison of the elimination between perfluorinated fatty acids with different carbon chain length in rats. Chem Biol Interact 134: 203–216. 10.1016/S0009-2797(01)00155-7.11311214
Kvalem, HE; Nygaard, UC; Lødrup Carlsen, KC; Carlsen, KH; Haug, LS; Granum, B. (2020). Perfluoroalkyl substances, airways infections, allergy and asthma related health outcomes - Implications of gender, exposure period and study design. Environ Int 134: 105259. 10.1016/j.envint.2019.105259.31733527
Kwon, EJ; Shin, JS; Kim, BM; Shah-Kulkarni, S; Park, H; Kho, YL; Park, EA; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects birth weight through GSTM1 polymorphism. J Occup Environ Med 58: e198–e205. 10.1097/JOM.0000000000000739.27206125
Langley, AE; Pilcher, GD. (1985). Thyroid, bradycardic and hypothermic effects of perfluoro-n-decanoic acid in rats. J Toxicol Environ Health 15: 485–491. 10.1080/15287398509530675.4032495
Lankova, D; Lacina, O; Pulkrabova, J; Hajslova, J. (2013). The determination of perfluoroalkyl substances, brominated flame retardants and their metabolites in human breast milk and infant formula. Talanta 117: 318–325. 10.1016/j.talanta.2013.08.040.24209347
Lau, C. (2015). Perfluorinated compounds: An overview. In DeWitt JC (Ed.), Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances (pp. 1–21). New York: Springer. 10.1007/978-3-319-15518-0_1.
Lee, ES; Han, S; Oh, JE. (2016). Association between perfluorinated compound concentrations in cord serum and birth weight using multiple regression models. Reprod Toxicol 59: 53–59. 10.1016/j.reprotox.2015.10.020.26562669
Lee, JK; Kim, SH. (2018). Correlation between mast cell-mediated allergic inflammation and length of perfluorinated compounds. J Toxicol Environ Health A 81: 1–12. 10.1080/15287394.2018.1440188.29173133
Lee, YA; Kim, JH; Jung, HW; Lim, YH; Bae, S; Kho, Y; Hong, YC; Shin, CH; Yang, SW. (2018). The serum concentrations of perfluoroalkyl compounds were inversely associated with growth parameters in 2-year old children. Sci Total Environ 628-629: 226–232. 10.1016/j.scitotenv.2018.02.050.29438932
Leehy, KA; Regan Anderson, TM; Daniel, AR; Lange, CA; Ostrander, JH. (2016). Modifications to glucocorticoid and progesterone receptors alter cell fate in breast cancer [Review]. J Mol Endocrinol 56: R99–R114. 10.1530/JME-15-0322.26831511
Lefevre, J; Mcclintock, MK. (1988). Reproductive senescence in female rats - A longitudinal-study of individual-differences in estrous cycles and behavior. Biol Reprod 38: 780–789. 10.1095/biolreprod38.4.780.3401536
Lenters, V; Portengen, L; Rignell-Hydbom, A; Jönsson, BA; Lindh, CH; Piersma, AH; Toft, G; Bonde, JP; Heederik, D; Rylander, L; Vermeulen, R. (2016). Prenatal phthalate, perfluoroalkyl acid, and organochlorine exposures and term birth weight in three birth cohorts: multi-pollutant models based on elastic net regression. Environ Health Perspect 124: 365–372. 10.1289/ehp.1408933.26115335
Levin, S; Selmer, D; Z, R. (1993). Effects of two weeks of feed restriction on some common toxicologic parameters in Sprague-Dawley rats. Toxicol Pathol 21: 1–14. 10.1177/019262339302100101.8378702
Levitt, D; Liss, A. (1986). Toxicity of perfluorinated fatty acids for human and murine B cell lines. Toxicol Appl Pharmacol 86: 1–11. 10.1016/0041-008x(86)90394-7.3764929
Lewiński, A; Stasiak, M. (2017). Physiopathology, diagnosis, and treatment of secondary hypothyroidism. In Hypothalamic-Pituitary Diseases. Basel, Switzerland: Springer International Publishing. 10.1007/978-3-319-38681-2_7-1.
Li, J; Cai, D; Chu, C; Li, QQ; Zhou, Y; Hu, LW; Yang, BY; Dong, GH; Zeng, XW; Chen, D. (2020a). Transplacental Transfer of Per- and Polyfluoroalkyl Substances (PFASs): Differences between Preterm and Full-Term Deliveries and Associations with Placental Transporter mRNA Expression. Environ Sci Technol 54: 5062–5070. 10.1021/acs.est.0c00829.32208722
Li, J; Cao, H; Feng, H; Xue, Q; Zhang, A; Fu, J. (2020b). Evaluation of the estrogenic/antiestrogenic activities of perfluoroalkyl substances and their interactions with the human estrogen receptor by combining in vitro assays and in silico modeling. Environ Sci Technol 54: 14514–14524. 10.1021/acs.est.0c03468.33111528
Li, KM; Zhao, Q; Fan, ZY; Jia, SY; Liu, Q; Liu, FY; Liu, SL. (2022). The toxicity of perfluorodecanoic acid is mainly manifested as a deflected immune function. Mol Biol Rep 49: 4365–4376. 10.1007/s11033-022-07272-w.35233679
Li, LQ; Shigematsu, Y; Hamada, M; Hiwada, K. (2001). Relative wall thickness is an independent predictor of left ventricular systolic and diastolic dysfunctions in essential hypertension. Hypertens Res 24: 493–499. 10.1291/hypres.24.493.11675942
Li, M; Zeng, XW; Qian, ZM; Vaughn, MG; Sauvé, S; Paul, G; Lin, S; Lu, L; Hu, LW; Yang, BY; Zhou, Y; Qin, XD; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Fu, C; Dong, GH. (2017). Isomers of perfluorooctanesulfonate (PFOS) in cord serum and birth outcomes in China: Guangzhou Birth Cohort Study. Environ Int 102: 1–8. 10.1016/j.envint.2017.03.006.28297681
Liang, H; Wang, Z; Miao, M; Tian, Y; Zhou, Y; Wen, S; Chen, Y; Sun, X; Yuan, W. (2020). Prenatal exposure to perfluoroalkyl substances and thyroid hormone concentrations in cord plasma in a Chinese birth cohort. Environ Health 19: 127. 10.1186/s12940-020-00679-7.33243245
Liao, Q; Tang, P; Fan, H; Song, Y; Liang, J; Huang, H; Pan, D; Mo, M; Leilei; Lin, M; Chen, J; Wei, H; Long, J; Shao, Y; Zeng, X; Liu, S; Huang, D; Qiu, X. (2023). Association between maternal exposure to per- and polyfluoroalkyl substances and serum markers of liver function during pregnancy in China: A mixture-based approach. Environ Pollut 323: 121348. 10.1016/j.envpol.2023.121348.36842621
Liew, Z; Luo, J; Nohr, EA; Bech, BH; Bossi, R; Arah, OA; Olsen, J. (2020). Maternal plasma perfluoroalkyl substances and miscarriage: a nested case-control study in the Danish National Birth Cohort. Environ Health Perspect 128: 47007. 10.1289/EHP6202.32319790
Liew, Z; Ritz, B; Bach, CC; Asarnow, RF; Bech, BH; Nohr, EA; Bossi, R; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J. (2018). Prenatal exposure to perfluoroalkyl substances and iq scores at age 5; a study in the danish national birth cohort. Environ Health Perspect 126: 067004. 10.1289/EHP2754.29897723
Liew, Z; Ritz, B; Bonefeld-Jørgensen, EC; Henriksen, TB; Nohr, EA; Bech, BH; Fei, C; Bossi, R; von Ehrenstein, OS; Streja, E; Uldall, P; Olsen, J. (2014). Prenatal exposure to perfluoroalkyl substances and the risk of congenital cerebral palsy in children. Am J Epidemiol 180: 574–581. 10.1093/aje/kwu179.25139206
Liew, Z; Ritz, B; von Ehrenstein, OS; Bech, BH; Nohr, EA; Fei, C; Bossi, R; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J. (2015). Attention deficit/hyperactivity disorder and childhood autism in association with prenatal exposure to perfluoroalkyl substances: A nested case-control study in the Danish National Birth Cohort. Environ Health Perspect 123: 367–373. 10.1289/ehp.1408412.25616253
Lim, JJ; Suh, Y; Faustman, EM; Cui, JY. (2021). Regulation of transporters by perfluorinated carboxylic acids in HepaRG cells. Drug Metab Dispos 50: 1396–1413. 10.1124/dmd.121.000477.34857530
Lin, HW; Feng, HX; Chen, L; Yuan, XJ; Tan, Z. (2020a). Maternal exposure to environmental endocrine disruptors during pregnancy is associated with pediatric germ cell tumors. Nagoya J Med Sci 82: 323–333. 10.18999/nagjms.82.2.323.32581411
Lin, TW; Chen, MK; Lin, CC; Chen, MH; Tsai, MS; Chan, DC; Hung, KY; Chen, PC. (2020b). Association between exposure to perfluoroalkyl substances and metabolic syndrome and related outcomes among older residents living near a Science Park in Taiwan. Int J Hyg Environ Health 230: 113607. 10.1016/j.ijheh.2020.113607.32919137
Lind, DV; Priskorn, L; Lassen, TH; Nielsen, F; Kyhl, HB; Kristensen, DM; Christesen, HT; Jørgensen, JS; Grandjean, P; Jensen, TK. (2017a). Prenatal exposure to perfluoroalkyl substances and anogenital distance at 3 months of age in a Danish mother-child cohort. Reprod Toxicol 68: 200–206. 10.1016/j.reprotox.2016.08.019.27592399
Lind, PM; Lind, L; Salihovic, S; Ahlström, H; Michaelsson, K; Kullberg, J; Strand, R. (2022). Serum levels of perfluoroalkyl substances (PFAS) and body composition - A cross-sectional study in a middle-aged population. Environ Res 209: 112677. 10.1016/j.envres.2022.112677.35074350
Lind, PM; Salihovic, S; van Bavel, B; Lind, L. (2017b). Circulating levels of perfluoroalkyl substances (PFASs) and carotid artery atherosclerosis. Environ Res 152: 157–164. 10.1016/j.envres.2016.10.002.27771570
Liu, B; Wei, B; Mo, M; Song, Y; Tang, C; Tang, P; Guo, X; Tan, C; Liu, S; Huang, D; Qiu, X. (2021a). Exposure to perfluoroalkyl substances in early pregnancy and the risk of hypertensive disorders of pregnancy: A nested case-control study in Guangxi, China. Chemosphere 288: 132468. 10.1016/j.chemosphere.2021.132468.34624345
Liu, C; Xu, X; Huo, X, ia. (2014). Anogenital distance and its application in environmental health research [Review]. Environ Sci Pollut Res Int 21: 5457–5464. 10.1007/s11356-014-2570-z.24474565
Liu, F; Fan, Z; Song, N; Han, M; Yan, M; Guo, LH; Jihui, J; Liu, S. (2019a). XRCC4, which is inhibited by PFDA, regulates DNA damage repair and cell chemosensitivity. J Cell Biochem 120: 12665–12676. 10.1002/jcb.28534.30834581
Liu, G; Dhana, K; Furtado, JD; Rood, J; Zong, G; Liang, L; Qi, L; Bray, GA; Dejonge, L; Coull, B; Grandjean, P; Sun, Q. (2018). Perfluoroalkyl substances and changes in body weight and resting metabolic rate in response to weight-loss diets: A prospective study. PLoS Med 15: e1002502. 10.1371/journal.pmed.1002502.29438414
Liu, G; Zhang, B; Hu, Y; Rood, J; Liang, L; Qi, L; Bray, GA; Dejonge, L; Coull, B; Grandjean, P; Furtado, JD; Sun, Q. (2020a). Associations of Perfluoroalkyl substances with blood lipids and Apolipoproteins in lipoprotein subspecies: the POUNDS-lost study. Environ Health 19: 5. 10.1186/s12940-020-0561-8.31931806
Liu, H; Pan, Y; Jin, S; Li, Y; Zhao, L; Sun, X; Cui, Q; Zhang, B; Zheng, T; Xia, W; Zhou, A; Campana, AM; Dai, J; Xu, S. (2020b). Associations of per-/polyfluoroalkyl substances with glucocorticoids and progestogens in newborns. Environ Int 140: 105636. 10.1016/j.envint.2020.105636.32474218
Liu, J; Li, J; Liu, Y; Chan, HM; Zhao, Y; Cai, Z; Wu, Y. (2011). Comparison on gestation and lactation exposure of perfluorinated compounds for newborns. Environ Int 37: 1206–1212. 10.1016/j.envint.2011.05.001.21620474
Liu, JJ; Cui, XX; Tan, YW; Dong, PX; Ou, YQ; Li, QQ; Chu, C; Wu, LY; Liang, LX; Qin, SJ; Zeeshan, M; Zhou, Y; Hu, LW; Liu, RQ; Zeng, XW; Dong, GH; Zhao, XM. (2022). Per- and perfluoroalkyl substances alternatives, mixtures and liver function in adults: A community-based population study in China. Environ Int 163: 107179. 10.1016/j.envint.2022.107179.35325771
Liu, M; Zhang, G; Meng, L; Han, X; Li, Y; Shi, Y; Li, A; Turyk, ME; Zhang, Q; Jiang, G. (2021b). Associations between novel and legacy per- and polyfluoroalkyl substances in human serum and thyroid cancer: A case and healthy population in Shandong Province, East China. Environ Sci Technol 56: 6144–6151. 10.1021/acs.est.1c02850.34618433
Liu, X; Zhang, L; Chen, L; Li, J; Wang, Y; Wang, J; Meng, G; Chi, M; Zhao, Y; Chen, H; Wu, Y. (2019b). Structure-based investigation on the association between perfluoroalkyl acids exposure and both gestational diabetes mellitus and glucose homeostasis in pregnant women. Environ Int 127: 85–93. 10.1016/j.envint.2019.03.035.30909097
Lorber, M; Eaglesham, GE; Hobson, P; Toms, LM; Mueller, JF; Thompson, JS. (2015). The effect of ongoing blood loss on human serum concentrations of perfluorinated acids. Chemosphere 118: 170–177. 10.1016/j.chemosphere.2014.07.093.25180653
Louis, GM; Sapra, KJ; Barr, DB; Lu, Z; Sundaram, R. (2016). Preconception perfluoroalkyl and polyfluoroalkyl substances and incident pregnancy loss, LIFE Study. Reprod Toxicol 65: 11–17. 10.1016/j.reprotox.2016.06.011.27319395
Louis, GMB; Peterson, CM; Chen, Z; Hediger, ML; Croughan, MS; Sundaram, R; Stanford, JB; Fujimoto, VY; Varner, MW; Giudice, LC; Kennedy, A; Sun, L; Wu, Q; Kannan, K. (2012). Perfluorochemicals and endometriosis: The ENDO study. Epidemiology 23: 799–805. 10.1097/EDE.0b013e31826cc0cf.22992575
Lum, KJ; Sundaram, R; Barr, DB; Louis, TA; Buck Louis, GM. (2017). Perfluoroalkyl Chemicals, Menstrual Cycle Length, and Fecundity: Findings from a Prospective Pregnancy Study. Epidemiology 28: 90–98. 10.1097/EDE.0000000000000552.27541842
Lumley, T. (2004). Analysis of complex survey samples. J Stat Softw 9. 10.18637/jss.v009.i08.
Lumley, T. (2023). Survey: Analysis of complex survey samples (Version 4.2–1). Retrieved from https://cran.r-project.org/package=survey
Luo, D; Wu, WX; Pan, YA; Du, BB; Shen, MJ; Zeng, LX. (2021). Associations of prenatal exposure to per- and polyfluoroalkyl substances with the neonatal birth size and hormones in the growth hormone/insulin-like growth factor axis. Environ Sci Technol 55: 11859–11873. 10.1021/acs.est.1c02670.34378915
Luo, J; Xiao, J; Gao, Y; Ramlau-Hansen, CH; Toft, G; Li, J; Obel, C; Andersen, SL; Deziel, NC; Tseng, WL; Inoue, K; Bonefeld-Jørgensen, EC; Olsen, J; Liew, Z. (2020). Prenatal exposure to perfluoroalkyl substances and behavioral difficulties in childhood at 7 and 11 years. Res, Environ 191: 110111. 10.1016/j.envres.2020.110111.
Luo, M; Tan, Z; Dai, M; Song, D; Lin, J; Xie, M; Yang, J; Sun, L; Wei, D; Zhao, J; Gonzalez, FJ; Liu, A. (2017). Dual action of peroxisome proliferator-activated receptor alpha in perfluorodecanoic acid-induced hepatotoxicity. Arch Toxicol 91: 897–907. 10.1007/s00204-016-1779-7.27344344
Lyall, K; Yau, VM; Hansen, R; Kharrazi, M; Yoshida, CK; Calafat, AM; Windham, G; Croen, LA. (2018). Prenatal maternal serum concentrations of per- and polyfluoroalkyl substances in association with autism spectrum disorder and intellectual disability. Environ Health Perspect 126: 017001. 10.1289/EHP1830.29298162
Maher, JM; Aleksunes, LM; Dieter, MZ; Tanaka, Y; Peters, JM; Manautou, JE; Klaassen, CD. (2008). Nrf2- and PPAR alpha-mediated regulation of hepatic Mrp transporters after exposure to perfluorooctanoic acid and perfluorodecanoic acid. Toxicol Sci 106: 319–328. 10.1093/toxsci/kfn177.18757529
Mamsen, LS; Björvang, RD; Mucs, D; Vinnars, MT; Papadogiannakis, N; Lindh, CH; Andersen, CY; Damdimopoulou, P. (2019). Concentrations of perfluoroalkyl substances (PFASs) in human embryonic and fetal organs from first, second, and third trimester pregnancies. Environ Int 124: 482–492. 10.1016/j.envint.2019.01.010.30684806
Mamsen, LS; Jönsson, BAG; Lindh, CH; Olesen, RH; Larsen, A; Ernst, E; Kelsey, TW; Andersen, CY. (2017). Concentration of perfluorinated compounds and cotinine in human foetal organs, placenta, and maternal plasma. Sci Total Environ 596-597: 97–105. 10.1016/j.scitotenv.2017.04.058.28426990
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Martinez, D; Costa, O; Santa-Marina, L; Pereda-Pereda, E; Schettgen, T; Sunyer, J; Vrijheid, M. (2017). Prenatal exposure to perfluoroalkyl substances and birth outcomes in a Spanish birth cohort. Int, Environ 108: 278–284. 10.1016/j.envint.2017.09.006.
Mariash, CN; Kaiser, FE; Schwartz, HL; Towle, HC; Oppenheimer, JH. (1980). Synergism of thyroid-hormone and high-carbohydrate diet in the induction of lipogenic enzymes in the rat - Mechanisms and implications. J Clin Invest 65: 1126–1134. 10.1172/JCI109766.7364940
Marty, MS; Allen, B; Chapin, RE; Cooper, R; Daston, GP; Flaws, JA; Foster, PMD; Makris, SL; Mylchreest, E; Sandler, D; Tyl, RW. (2009). Inter-laboratory control data for reproductive endpoints required in the OPPTS 870.3800/OECD 416 reproduction and fertility test. Birth Defects Res B Dev Reprod Toxicol 86: 470–489. 10.1002/bdrb.20208.19918951
Matthews, DR; Hosker, JP; Rudenski, AS; Naylor, BA; Treacher, DF; Turner, RC. (1985). Homeostasis model assessment: Insulin resistance and beta-cell function from fasting plasma glucose and insulin concentrations in man. Diabetologia 28: 412–419. 10.1007/BF00280883.3899825
Mattsson, K; Rignell-Hydbom, A; Holmberg, S; Thelin, A; Jönsson, BA; Lindh, CH; Sehlstedt, A; Rylander, L. (2015). Levels of perfluoroalkyl substances and risk of coronary heart disease: Findings from a population-based longitudinal study. Environ Res 142: 148–154. 10.1016/j.envres.2015.06.033.26142720
Mayer, C; Boehm, U. (2011). Female reproductive maturation in the absence of kisspeptin/GPR54 signaling. Nat Neurosci704-U297. 10.1038/nn.2818.
McComb, J; Mills, IG; Berntsen, HF; Ropstad, E; Verhaegen, S; Connolly, L. (2019). Human-based exposure levels of perfluoroalkyl acids may induce harmful effects to health by disrupting major components of androgen receptor signalling in vitro. Exposure and Health 12: 527–538. 10.1007/s12403-019-00318-8.
McCoy, JA; Bangma, JT; Reiner, JL; Bowden, JA; Schnorr, J; Slowey, M; OĽeary, T; Guillette, LJ; Parrott, BB. (2017). Associations between perfluorinated alkyl acids in blood and ovarian follicular fluid and ovarian function in women undergoing assisted reproductive treatment. Sci Total Environ 605-606: 9–17. 10.1016/j.scitotenv.2017.06.137.28651210
MDH (Minnesota Department of Health). (2019). Health Based Guidance for Water: Toxicological Summary for: Perfluorohexane sulfonate (PFHxS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfhxs.pdf.
Meng, Q; Inoue, K; Ritz, B; Olsen, J; Liew, Z. (2018). Prenatal exposure to perfluoroalkyl substances and birth outcomes; An updated analysis from the Danish national birth cohort. Int J Environ Res Public Health 15: 1832. 10.3390/ijerph15091832.30149566
Mi, X; Lin, SQ; Zhang, XF; Li, JJ; Pei, LJ; Jin, F; Liao, Q; Xie, LM; Wei, LC; Hao, CJ; Zhang, YW; Li, W. (2022). Maternal perfluorinated compound exposure and risk of early pregnancy loss: A nested case-control study [Letter]. Biomed Environ Sci 35: 174–179. 10.3967/bes2022.026.35197186
Miller, BH; Takahashi, JS. (2014). Central circadian control of female reproductive function [Review]. Front Endocrinol (Lausanne) 4: 195. 10.3389/fendo.2013.00195.24478756
Mira-Escolano, MP; Mendiola, J; Mínguez-Alarcón, L; Melgarejo, M; Cutillas-Tolín, A; Roca, M; López-Espín, JJ; Noguera-Velasco, JA; Torres-Cantero, AM. (2014). Longer anogenital distance is associated with higher testosterone levels in women: a cross-sectional study. BJOG 121: 1359–1364. 10.1111/1471-0528.12627.25250921
Mobacke, I; Lind, L; Dunder, L; Salihovic, S; Lind, PM. (2018). Circulating levels of perfluoroalkyl substances and left ventricular geometry of the heart in the elderly. Environ Int 115: 295–300. 10.1016/j.envint.2018.03.033.29621717
Mora, AM; Fleisch, AF; Rifas-Shiman, SL; Woo Baidal, JA; Pardo, L; Webster, TF; Calafat, AM; Ye, X; Oken, E; Sagiv, SK. (2018). Early life exposure to per- and polyfluoroalkyl substances and mid-childhood lipid and alanine aminotransferase levels. Environ Int 111: 1–13. 10.1016/j.envint.2017.11.008.29156323
Morgan, RL; Thayer, KA; Bero, L; Bruce, N; Falck-Ytter, Y; Ghersi, D; Guyatt, G; Hooijmans, C; Langendam, M; Mandrioli, D; Mustafa, RA; Rehfuess, EA; Rooney, AA; Shea, B; Silbergeld, EK; Sutton, P; Wolfe, MS; Woodruff, TJ; Verbeek, JH; Holloway, AC; Santesso, N; Schünemann, HJ. (2016). GRADE: Assessing the quality of evidence in environmental and occupational health. Environ Int 92-93: 611–616. 10.1016/j.envint.2016.01.004.26827182
Myhr, BC; Lawlor, TE; Young, RR; Murli, H; Cifone, MA. (1990). Genotoxicity assessment of perfluorodecanoic acid using a battery of in vitro and in vivo/in vitro assays (pp. 80). Myhr, BC; Lawlor, TE; Young, RR; Murli, H; Cifone, MA.
Nakagawa, T; Ramdhan, DH; Tanaka, N; Naito, H; Tamada, H; Ito, Y; Li, Y; Hayashi, Y; Yamagishi, N; Yanagiba, Y; Aoyama, T; Gonzalez, FJ; Nakajima, T. (2012). Modulation of ammonium perfluorooctanoate-induced hepatic damage by genetically different PPARα in mice. Arch Toxicol 86: 63–74. 10.1007/s00204-011-0704-3.21499893
Natarajan, S; Lipsitz, S. R.; Nietert, PJ. (2002). Self-report of high cholesterol - Determinants of validity in US adults. Am J Prev Med 23: 13–21. 10.1016/s0749-3797(02)00446-4.
Needham, LL; Grandjean, P; Heinzow, B; Jørgensen, PJ; Nielsen, F; Patterson, DG; Sjödin, A; Turner, WE; Weihe, P. (2011). Partition of environmental chemicals between maternal and fetal blood and tissues. Environ Sci Technol 45: 1121–1126. 10.1021/es1019614.21166449
Nelson, DL; Frazier, DE, Jr; Ericson, JE; Tarr, MJ; Mathes, LE. (1992). The effects of perfluorodecanoic acid (PFDA) on humoral, cellular, and innate immunity in Fischer 344 rats. Immunopharmacol Immunotoxicol 14: 925–938. 10.3109/08923979209009242.1294628
Nian, M; Li, QQ; Bloom, M; Qian, ZM; Syberg, KM; Vaughn, MG; Wang, SQ; Wei, Q; Zeeshan, M; Gurram, N; Chu, C; Wang, J; Tian, YP; Hu, LW; Liu, KK; Yang, BY; Liu, RQ; Feng, D; Zeng, XW; Dong, GH. (2019). Liver function biomarkers disorder is associated with exposure to perfluoroalkyl acids in adults: Isomers of C8 Health Project in China. Environ Res 172: 81–88. 10.1016/j.envres.2019.02.013.30776734
Nigam, PK. (2011). Serum lipid profile: fasting or non-fasting? Indian J Clin Biochem 26: 96–97. 10.1007/s12291-010-0095-x.22211025
NIH (National Institutes of Health). (2020). The PhenX Toolkit: protocol - lipid profile. Available online at https://www.phenxtoolkit.org/protocols/view/40201 (accessed
Nilsson, H; Kärrman, A; Westberg, H; Rotander, A; van Bavel, B; Lindström, G. (2010). A time trend study of significantly elevated perfluorocarboxylate levels in humans after using fluorinated ski wax. Environ Sci Technol 44: 2150–2155. 10.1021/es9034733.20158198
Niu, J; Liang, H; Tian, Y; Yuan, W; Xiao, H; Hu, H; Sun, X; Song, X; Wen, S; Yang, L; Ren, Y; Miao, M. (2019). Prenatal plasma concentrations of Perfluoroalkyl and polyfluoroalkyl substances and neuropsychological development in children at four years of age. Environ Health 18: 53. 10.1186/s12940-019-0493-3.31196101
NLM (National Library of Medicine). (2013). HSDB: Perfluoro-n-nonanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8040 (accessed
NLM (National Library of Medicine). (2017). HSDB: Perfluorohexanesulfonic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8274 (accessed
NTP (National Toxicology Program). (2005). Study information: CEBS accession number 002-02652-0001-0000-8: Perfluorodecanoic acid. Available online at https://tools.niehs.nih.gov/cebs3/ntpViews/?studyNumber=002-02652-0001-0000-8 (accessed August 25, 2017).
NTP (National Toxicology Program). (2012). Study information: CEBS accession number 002-02652-0003-0000-0: Perfluorodecanoic acid. Available online at https://tools.niehs.nih.gov/cebs3/ntpViews/?studyNumber=002-02652-0003-0000-0 (accessed August 25, 2017).
NTP (National Toxicology Program). (2016). NTP Monograph: Immunotoxicity associated with exposure to perfluorooctanoic acid (PFOA) or perfluorooctane sulfonate (PFOS). Research Triangle Park, NC: U.S. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pfoa_pfos/pfoa_pfosmonograph_508.pdf.
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C20615) of perfluorodecanoic acid (PFDA) (335–76-2) on Harlan Sprague-Dawley rats exposed via gavage [NTP]. U.S. Department of Health and Human Services. 10.22427/NTP-DATA-002-02652-0004-0000-1.
NTP (National Toxicology Program). (2019). NTP technical report on the toxicity studies of perfluoroalkyl carboxylates (perfluorohexanoic acid, perfluorooctanoic acid, perfluorononanoic acid, and perfluorodecanoic acid) administered by gavage to Sprague Dawley (Hsd:Sprague Dawley SD) rats (revised). (Toxicity Report 97). Research Triangle Park, NC. 10.22427/NTP-TOX-97.
O'Shaughnessy, KL; Thomas, SE; Spring, S. R.; Ford, JL; Ford, RL; Gilbert, ME. (2019). A transient window of hypothyroidism alters neural progenitor cells and results in abnormal brain development. Sci Rep 9: 4662. 10.1038/s41598-019-40249-7.30874585
OECD (Organisation for Economic Co-operation and Development). (2018). Toward a new comprehensive global database of per- and polyfluoroalkyl substances (PFASs): Summary report on updating the OECD 2007 list of per- and polyfluoroalkyl substances (PFASs). (ENV/JM/MONO(2018)7). Paris, France. http://www.oecd.org/chemicalsafety/portal-perfluorinated-chemicals/.
Ohmori, K; Kudo, N; Katayama, K; Kawashima, Y. (2003). Comparison of the toxicokinetics between perfluorocarboxylic acids with different carbon chain length. Toxicology 184: 135–140. 10.1016/S0300-483X(02)00573-5.12499116
Okada, E; Sasaki, S; Kashino, I; Matsuura, H; Miyashita, C; Kobayashi, S; Itoh, K; Ikeno, T; Tamakoshi, A; Kishi, R. (2014). Prenatal exposure to perfluoroalkyl acids and allergic diseases in early childhood. Environ Int 65: 127–134. 10.1016/j.envint.2014.01.007.24486970
Olsen, GW; Burris, JM; Ehresman, DJ; Froehlich, JW; Seacat, AM; Butenhoff, JL; Zobel, LR. (2007). Half-life of serum elimination of perfluorooctanesulfonate, perfluorohexanesulfonate, and perfluorooctanoate in retired fluorochemical production workers. Environ Health Perspect 115: 1298–1305. 10.1289/ehp.10009.17805419
Olsen, GW; Mair, DC; Lange, CC; Harrington, LM; Church, TR; Goldberg, CL; Herron, RM; Hanna, H; Nobiletti, JB; Rios, JA; Reagen, WK; Ley, CA. (2017). Per- and polyfluoroalkyl substances (PFAS) in American Red Cross adult blood donors, 2000-2015. Environ Res 157: 87–95. 10.1016/j.envres.2017.05.013.28528142
Olson, CT; Andersen, ME. (1983). The acute toxicity of perfluorooctanoic and perfluorodecanoic acids in male rats and effects on tissue fatty acids. Toxicol Appl Pharmacol 70: 362–372. 10.1016/0041-008x(83)90154-0.6636169
Omoike, OE; Pack, RP; Mamudu, HM; Liu, Y; Strasser, S; Zheng, S; Okoro, J; Wang, L. (2020). Association between per and polyfluoroalkyl substances and markers of inflammation and oxidative stress. Environ Res 196: 110361. 10.1016/j.envres.2020.110361.33131681
Omoike, OE; Pack, RP; Mamudu, HM; Liu, Y; Wang, L. (2021). A cross-sectional study of the association between perfluorinated chemical exposure and cancers related to deregulation of estrogen receptors. Environ Res 196: 110329. 10.1016/j.envres.2020.110329.33068574
Osmond, C; Barker, DJ. (2000). Fetal, infant, and childhood growth are predictors of coronary heart disease, diabetes, and hypertension in adult men and women [Review]. Environ Health Perspect 108: 545–553. 10.2307/3454545.
Ou, Y; Zeng, X; Lin, S; Bloom, MS; Han, F; Xiao, X; Wang, H; Matala, R; Li, X; Qu, Y; Nie, Z; Dong, G; Liu, X. (2021). Gestational exposure to perfluoroalkyl substances and congenital heart defects: A nested case-control pilot study. Environ Int 154: 106567. 10.1016/j.envint.2021.106567.33882431
Oulhote, Y; Steuerwald, U; Debes, F; Weihe, P; Grandjean, P. (2016). Behavioral difficulties in 7-year old children in relation to developmental exposure to perfluorinated alkyl substances [Review]. Environ Int 97: 237–245. 10.1016/j.envint.2016.09.015.27692925
Padula, AM; Ning, X; Bakre, S; Barrett, ES; Bastain, T; Bennett, DH; Bloom, MS; Breton, CV; Dunlop, AL; Eick, SM; Ferrara, A; Fleisch, A; Geiger, S; Goin, DE; Kannan, K; Karagas, MR; Korrick, S; Meeker, JD; Morello-Frosch, R. (2023). Birth outcomes in relation to prenatal exposure to per-and polyfluoroalkyl substances and stress in the environmental influences on child health outcomes (echo) program [Supplemental Data]. Environ Health Perspect 131: (037006) 037001–037011. 10.1289/EHP10723.36856429
Pan, Y; Cui, Q; Wang, J; Sheng, N; Jing, J; Yao, B; Dai, J. (2019). Profiles of emerging and legacy per-/polyfluoroalkyl substances in matched serum and semen samples: New implications for human semen quality. Environ Health Perspect 127: 127005. 10.1289/EHP4431.31841032
Pan, Y; Zhu, Y; Zheng, T; Cui, Q; Buka, SL; Zhang, B; Guo, Y; Xia, W; Yeung, LW; Li, Y; Zhou, A; Qiu, L; Liu, H; Jiang, M; Wu, C; Xu, S; Dai, J. (2017). Novel Chlorinated Polyfluorinated Ether Sulfonates and Legacy Per-/Polyfluoroalkyl Substances: Placental Transfer and Relationship with Serum Albumin and Glomerular Filtration Rate. Environ Sci Technol 51: 634–644. 10.1021/acs.est.6b04590.27931097
Park, JH; Choi, J; Jun, DW; Han, SW; Yeo, YH; Nguyen, MH. (2019). Low Alanine Aminotransferase Cut-Off for Predicting Liver Outcomes; A Nationwide Population-Based Longitudinal Cohort Study. J Clin Med 8. 10.3390/jcm8091445.
Pelch, KE; Reade, A; Kwiatkowski, CF; Merced-Nieves, FM; Cavalier, H; Schultz, K; Wolffe, T; Varshavsky, J. (2022). The PFAS-Tox Database: A systematic evidence map of health studies on 29 per- and polyfluoroalkyl substances. Environ Int 167: 107408. 10.1016/j.envint.2022.107408.35908389
Pérez, F; Llorca, M; Köck-Schulmeyer, M; Škrbić, B; Oliveira, LS; da Boit Martinello, K; Al-Dhabi, NA; Antić, I; Farré, M; Barceló, D. (2014). Assessment of perfluoroalkyl substances in food items at global scale. Environ Res 135: 181–189. 10.1016/j.envres.2014.08.004.25282275
Pérez, F; Nadal, M; Navarro-Ortega, A; Fàbrega, F; Domingo, JL; Barceló, D; Farré, M. (2013). Accumulation of perfluoroalkyl substances in human tissues. Environ Int 59: 354–362. 10.1016/j.envint.2013.06.004.23892228
Permadi, H; Lundgren, B; Andersson, K; Depierre, JW. (1992). Effects of perfluoro fatty acids on xenobiotic-metabolizing enzymes, enzymes which detoxify reactive forms of oxygen and lipid peroxidation in mouse liver. Biochem Pharmacol 44: 1183–1191. 10.1016/0006-2952(92)90383-T.1417940
Permadi, H; Lundgren, B; Andersson, K; Sundberg, C; Depierre, JW. (1993). Effects of perfluoro fatty acids on peroxisome proliferation and mitochondrial size in mouse liver: dose and time factors and effect of chain length. Xenobiotica 23: 761–770. 10.3109/00498259309166782.8237058
Perng, W, ei; Rifas-Shiman, SL; Kramer, MS; Haugaard, LK; Oken, E; Gillman, MW; Belfort, MB. (2016). Early Weight Gain, Linear Growth, and Mid-Childhood Blood Pressure A Prospective Study in Project Viva. Hypertension 67: 301–308. 10.1161/HYPERTENSIONAHA.115.06635.26644238
Petersen, KU; Hærvig, KK; Flachs, EM; Bonde, JP; Lindh, C; Hougaard, KS; Toft, G; Ramlau-Hansen, CH; Tøttenborg, SS. (2022). Per- and polyfluoroalkyl substances (PFAS) and male reproductive function in young adulthood; a cross-sectional study. Environ Res 212: 113157. 10.1016/j.envres.2022.113157.35318009
Pirard, C; Dufour, P; Charlier, C. (2020). Background contamination of perfluoralkyl substances in a Belgian general population. Toxicol Lett 333: 13–21. 10.1016/j.toxlet.2020.07.015.32659468
Poothong, S; Thomsen, C; Padilla-Sanchez, JA; Papadopoulou, E; Haug, LS. (2017). Distribution of novel and well-known poly- and perfluoroalkyl substances (PFASs) in human serum, plasma, and whole blood. Environ Sci Technol 51: 13388–13396. 10.1021/acs.est.7b03299.29056041
Powers, RH; Aust, SD. (1986). The effects of nonadecafluoro-n-decanoic acid on serum retinol and hepatic retinyl palmitate hydrolase activity in male Sprague-Dawley rats. J Biochem Toxicol 1: 27–42. 10.1002/jbt.2570010204.3271875
Qin, XD; Qian, Z; Vaughn, MG; Huang, J; Ward, P; Zeng, XW; Zhou, Y; Zhu, Y; Yuan, P; Li, M; Bai, Z; Paul, G; Hao, YT; Chen, W; Chen, PC; Dong, GH; Lee, YL. (2016). Positive associations of serum perfluoroalkyl substances with uric acid and hyperuricemia in children from Taiwan. Environ Pollut 212: 519–524. 10.1016/j.envpol.2016.02.050.26970855
Rahman, ML; Zhang, C; Smarr, MM; Lee, S; Honda, M; Kannan, K; Tekola-Ayele, F; Buck Louis, GM. (2019). Persistent organic pollutants and gestational diabetes: A multi-center prospective cohort study of healthy US women. Environ Int 124: 249–258. 10.1016/j.envint.2019.01.027.30660025
Rantakokko, P; Männistö, V; Airaksinen, R; Koponen, J; Viluksela, M; Kiviranta, H; Pihlajamäki, J. (2015). Persistent organic pollutants and non-alcoholic fatty liver disease in morbidly obese patients: A cohort study. Environ Health 14: 79. 10.1186/s12940-015-0066-z.26420011
Reardon, AJF; Khodayari Moez, E; Dinu, I; Goruk, S; Field, CJ; Kinniburgh, DW; Macdonald, AM; Martin, JW; Study, A. (2019). Longitudinal analysis reveals early-pregnancy associations between perfluoroalkyl sulfonates and thyroid hormone status in a Canadian prospective birth cohort. Environ Int 129: 389–399. 10.1016/j.envint.2019.04.023.31150980
Ren, XM; Qin, WP; Cao, LY; Zhang, J; Yang, Y; Wan, B; Guo, LH. (2016). Binding interactions of perfluoroalkyl substances with thyroid hormone transport proteins and potential toxicological implications. Toxicology 366-367: 32–42. 10.1016/j.tox.2016.08.011.27528273
Ren, XM; Zhang, YF; Guo, LH; Qin, ZF; Lv, QY; Zhang, LY. (2015). Structure-activity relations in binding of perfluoroalkyl compounds to human thyroid hormone T3 receptor. Arch Toxicol 89: 233–242. 10.1007/s00204-014-1258-y.24819616
Ren, Y; Jin, L; Yang, F; Liang, H; Zhang, Z; Du, J; Song, X; Miao, M; Yuan, W. (2020). Concentrations of perfluoroalkyl and polyfluoroalkyl substances and blood glucose in pregnant women. Health, Environ 19: 88. 10.1186/s12940-020-00640-8.
Ribeiro-Filho, J; Piuvezam, MR; Leite, FC; Costa, HF; Calheiros, AS; Torres, RC; de Azevedo, CT; Martins, MA; Dias, C, daS; Bozza, PT. (2014). Curine inhibits mast cell-dependent responses in mice. J Ethnopharmacol 1118–1124. 10.1016/j.jep.2014.06.041.24969825
Robledo, CA; Yeung, E; Mendola, P; Sundaram, R; Maisog, J; Sweeney, AM; Barr, DB; Louis, GM. (2015). Preconception maternal and paternal exposure to persistent organic pollutants and birth size: the LIFE study. Environ Health Perspect 123: 88–94. 10.1289/ehp.1308016.25095280
Rogers, AM; Andersen, ME; Back, KC. (1982). Mutagenicity of 2, 3, 7, 8-tetrachlorodibenzo-p-dioxin and perfluoro-n-decanoic acid in L5178Y mouse-lymphoma cells. Mutat Res 105: 445–449. 10.1016/0165-7992(82)90192-0.7155164
Rosen, EM; Brantsæter, AL; Carroll, R; Haug, L; Singer, AB; Zhao, S; Ferguson, KK. (2018). Maternal Plasma Concentrations of Per- and polyfluoroalkyl Substances and Breastfeeding Duration in the Norwegian Mother and Child Cohort. Environmental Epidemiology 2: e027. 10.1097/EE9.0000000000000027.30298140
Rosen, MB; Das, KP; Rooney, J; Abbott, B; Lau, C; Corton, JC. (2017). PPARα-independent transcriptional targets of perfluoroalkyl acids revealed by transcript profiling. Toxicology 387: 95–107. 10.1016/j.tox.2017.05.013.28558994
Rosen, MB; Das, KP; Wood, CR; Wolf, CJ; Abbott, BD; Lau, C. (2013). Evaluation of perfluoroalkyl acid activity using primary mouse and human hepatocytes. Toxicology 308: 129–137. 10.1016/j.tox.2013.03.011.23567314
Rosen, MB; Lee, JS; Ren, H; Vallanat, B; Liu, J; Waalkes, MP; Abbott, BD; Lau, C; Corton, JC. (2008). Toxicogenomic dissection of the perfluorooctanoic acid transcript profile in mouse liver: evidence for the involvement of nuclear receptors PPAR alpha and CAR. Toxicol Sci 103: 46–56. 10.1093/toxsci/kfn025.18281256
Rosen, MB; Schmid, JR; Corton, JC; Zehr, RD; Das, KP; Abbott, BD; Lau, C. (2010). Gene expression profiling in wild-type and PPAR alpha-null mice exposed to perfluorooctane sulfonate reveals PPAR alpha-independent effects. PPAR Research 2010: 794739. 10.1155/2010/794739.20936131
Rosenmai, AK; Ahrens, L; le Godec, T; Lundqvist, J; Oskarsson, A. (2018). Relationship between peroxisome proliferator-activated receptor alpha activity and cellular concentration of 14 perfluoroalkyl substances in HepG2 cells. J Appl Toxicol 38: 219–226. 10.1002/jat.3515.28857218
Routti, H; Berg, MK; Lille-Langøy, R; Øygarden, L; Harju, M; Dietz, R; Sonne, C; Goksøyr, A. (2019). Environmental contaminants modulate the transcriptional activity of polar bear (Ursus maritimus) and human peroxisome proliferator-activated receptor alpha (PPARα). Sci Rep 9: 6918. 10.1038/s41598-019-43337-w.31061404
Sagiv, SK; Rifas-Shiman, SL; Fleisch, AF; Webster, TF; Calafat, AM; Ye, X; Gillman, MW; Oken, E. (2018). Early Pregnancy Perfluoroalkyl Substance Plasma Concentrations and Birth Outcomes in Project Viva: Confounded by Pregnancy Hemodynamics? Am J Epidemiol 187: 793–802. 10.1093/aje/kwx332.29155920
Salazar-Martinez, E; Romano-Riquer, P; Yanez-Marquez, E; Longnecker, MP; Hernandez-Avila, M. (2004). Anogenital distance in human male and female newborns: a descriptive, cross-sectional study. Environ Health 3: 8–13. 10.1186/1476-069x-3-8.15363098
Salihovic, S; Stubleski, J; Kärrman, A; Larsson, A; Fall, T; Lind, L; Lind, PM. (2018). Changes in markers of liver function in relation to changes in perfluoroalkyl substances - A longitudinal study. Environ Int 117: 196–203. 10.1016/j.envint.2018.04.052.29754000
Sathyanarayana, S; Beard, L; Zhou, C; Grady, R. (2010). Measurement and correlates of ano-genital distance in healthy, newborn infants. Int J Androl 33: 317–323. 10.1111/j.1365-2605.2009.01044.x.20132349
Schecter, A; Malik-Bass, N; Calafat, AM; Kato, K; Colacino, JA; Gent, TL; Hynan, LS; Harris, TR; Malla, S; Birnbaum, L. (2012). Polyfluoroalkyl compounds in Texas children from birth through 12 years of age. Environ Health Perspect 120: 590–594. 10.1289/ehp.1104325.22182702
Schünemann, H; Hill, S; Guyatt, G; Akl, EA; Ahmed, F. (2011). The GRADE approach and Bradford Hill's criteria for causation. J Epidemiol Community Health 65: 392–395. 10.1136/jech.2010.119933.20947872
Scinicariello, F; Buser, MC; Balluz, L; Gehle, K; Murray, HE; Abadin, HG; Attanasio, R. (2020). Perfluoroalkyl acids, hyperuricemia and gout in adults: Analyses of NHANES 2009-2014. Chemosphere 259: 127446. 10.1016/j.chemosphere.2020.127446.32590180
Scott, HM; Mason, JI; Sharpe, RM. (2009). Steroidogenesis in the fetal testis and its susceptibility to disruption by exogenous compounds [Review]. Endocr Rev 30: 883–925. 10.1210/er.2009-0016.19887492
Sellers, RS; Mortan, D; Michael, B; Roome, N; Johnson, JK; Yano, BL; Perry, R; Schafer, K. (2007). Society of toxicologic pathology position paper: Organ weight recommendations for toxicology studies [Review]. Toxicol Pathol 35: 751–755. 10.1080/01926230701595300.17849358
Seo, SH; Son, MH; Choi, SD; Lee, DH; Chang, YS. (2018). Influence of exposure to perfluoroalkyl substances (PFASs) on the Korean general population: 10-year trend and health effects. Environ Int 113: 149–161. 10.1016/j.envint.2018.01.025.29425899
Shah-Kulkarni, S; Kim, BM; Hong, YC; Kim, HS; Kwon, EJ; Park, H; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects thyroid hormone levels in newborn girls. Environ Int 94: 607–613. 10.1016/j.envint.2016.06.024.27395336
Sharpe, RM. (2010). Environmental/lifestyle effects on spermatogenesis [Review]. Philos Trans R Soc Lond B Biol Sci 365: 1697–1712. 10.1098/rstb.2009.0206.20403879
Shi, Y; Yang, L; Li, J; Lai, J; Wang, Y; Zhao, Y; Wu, Y. (2017). Occurrence of perfluoroalkyl substances in cord serum and association with growth indicators in newborns from Beijing. Chemosphere 169: 396–402. 10.1016/j.chemosphere.2016.11.050.27886542
Shih, YH; Blomberg, AJ; Bind, MA; Holm, D; Nielsen, F; Heilmann, C; Weihe, P; Grandjean, P. (2021). Serum vaccine antibody concentrations in adults exposed to per- and polyfluoroalkyl substances: A birth cohort in the Faroe Islands. J Immunotoxicol 18: 85–92. 10.1080/1547691X.2021.1922957.34143710
Shin, HM; Bennett, DH; Calafat, AM; Tancredi, D; Hertz-Picciotto, I. (2020). Modeled prenatal exposure to per- and polyfluoroalkyl substances in association with child autism spectrum disorder: A case-control study. Environ Res 186: 109514. 10.1016/j.envres.2020.109514.32353786
Shinwell, ES; Shlomo, M. (2003). Measured length of normal term infants changes over the first two days of life. J Pediatr Endocrinol Metab 16: 537–540. 10.1515/jpem.2003.16.4.537.12793605
Sigman, M; Lipshultz, LI; Howards, SS. (1997). Evaluation of the subfertile male. In Lipschultz LI; Howards SS (Eds.), Infertility in the male (3rd ed., pp. 173). St. Louis, MO: Mosby.
Singer, AB; Whitworth, KW; Haug, LS; Sabaredzovic, A; Impinen, A; Papadopoulou, E; Longnecker, MP. (2018). Menstrual cycle characteristics as determinants of plasma concentrations of perfluoroalkyl substances (PFASs) in the Norwegian Mother and Child Cohort (MoBa study). Environ Res 166: 78–85. 10.1016/j.envres.2018.05.019.29879567
Skogheim, TS; Villanger, GD; Weyde, KVF; Engel, SM; Surén, P; Øie, MG; Skogan, AH; Biele, G; Zeiner, P; Øvergaard, KR; Haug, LS; Sabaredzovic, A; Aase, H. (2020). Prenatal exposure to perfluoroalkyl substances and associations with symptoms of attention-deficit/hyperactivity disorder and cognitive functions in preschool children. Int J Hyg Environ Health 223: 80–92. 10.1016/j.ijheh.2019.10.003.31653559
Skogheim, TS; Weyde, K, jell Vegard, F; Aase, H; Engel, SM; Suren, P; Oie, MG; Biele, G; Reichborn-Kjennerud, T; Brantsaeter, AL; Haug, LS; Sabaredzovic, A; Auyeung, B; Villanger, GD. (2021). Prenatal exposure to per- and polyfluoroalkyl substances (PFAS) and associations with attention-deficit/hyperactivity disorder and autism spectrum disorder in children. Environ Res 202: 111692. 10.1016/j.envres.2021.111692.34293314
Smit, LAM; Lenters, V; Høyer, BB; Lindh, CH; Pedersen, HS; Liermontova, I; Jönsson, BAG; Piersma, AH; Bonde, JP; Toft, G; Vermeulen, R; Heederik, D. (2015). Prenatal exposure to environmental chemical contaminants and asthma and eczema in school-age children. Allergy 70: 653–660. 10.1111/all.12605.25753462
Soukup, T; Zacharova, G; Smerdu, V; Jirmanova, I. (2001). Body, heart, thyroid gland and skeletal muscle weight changes in rats with altered thyroid status. Physiol Res 50: 619–626.11829324
Stahl, LL; Snyder, BD; Olsen, AR; Kincaid, TM; Wathen, JB; Mccarty, HB. (2014). Perfluorinated compounds in fish from U.S. urban rivers and the Great Lakes. Sci Total Environ 499: 185–195. 10.1016/j.scitotenv.2014.07.126.25190044
Starling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Dabelea, D. (2019). Prenatal exposure to per- and polyfluoroalkyl substances and infant growth and adiposity: The healthy start study. Environ Int 131: 104983. 10.1016/j.envint.2019.104983.31284113
Starling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Ye, X; Dabelea, D. (2017). Perfluoroalkyl substances during pregnancy and offspring weight and adiposity at birth: Examining mediation by maternal fasting glucose in the healthy start study. Environ Health Perspect 125: 067016. 10.1289/EHP641.28669937
Starling, AP; Engel, SM; Richardson, DB; Baird, DD; Haug, LS; Stuebe, AM; Klungsoyr, K; Harmon, Q; Becher, G; Thomsen, C; Sabaredzovic, A; Eggesbo, M; Hoppin, JA; Travlos, GS; Wilson, RE; Trogstad, LI; Magnus, P, er; Longnecker, MP. (2014a). Perfluoroalkyl Substances During Pregnancy and Validated Preeclampsia Among Nulliparous Women in the Norwegian Mother and Child Cohort Study. Am J Epidemiol 179: 824–833. 10.1093/aje/kwt432.24557813
Starling, AP; Engel, SM; Whitworth, KW; Richardson, DB; Stuebe, AM; Daniels, JL; Haug, LS; Eggesbø, M; Becher, G; Sabaredzovic, A; Thomsen, C; Wilson, RE; Travlos, GS; Hoppin, JA; Baird, DD; Longnecker, MP. (2014b). Perfluoroalkyl substances and lipid concentrations in plasma during pregnancy among women in the Norwegian Mother and Child Cohort Study. Environ Int 62: 104–112. 10.1016/j.envint.2013.10.004.24189199
Steenland, K; Barry, V; Savitz, D. (2018). Serum perfluorooctanoic acid and birthweight: an updated meta-analysis with bias analysis. Epidemiology 29: 765–776. 10.1097/EDE.0000000000000903.30063543
Sterchele, PF; Vanden Heuvel, JP; Davis, JW; Shrago, E; Knudsen, J; Peterson, RE. (1994). Induction of hepatic acyl-CoA-binding protein and liver fatty acid-binding protein by perfluorodecanoic acid in rats. Lack of correlation with hepatic long-chain acyl-CoA levels. Biochem Pharmacol 48: 955–966. 10.1016/0006-2952(94)90366-2.8093108
Strynar, MJ; Lindstrom, AB. (2008). Perfluorinated compounds in house dust from Ohio and North Carolina, USA. Environ Sci Technol 42: 3751–3756. 10.1021/es7032058.18546718
Stubleski, J; Salihovic, S; Lind, L; Lind, PM; van Bavel, B; Kärrman, A. (2016). Changes in serum levels of perfluoroalkyl substances during a 10-year follow-up period in a large population-based cohort. Environ Int 95: 86–92. 10.1016/j.envint.2016.08.002.27542758
Sun, Q; Zong, G; Valvi, D; Nielsen, F; Coull, B; Grandjean, P. (2018). Plasma concentrations of perfluoroalkyl substances and risk of Type 2 diabetes: A prospective investigation among women, U.S.. Environ Health Perspect 126: 037001. 10.1289/EHP2619.29498927
Sunderland, EM; Hu, XC; Dassuncao, C; Tokranov, AK; Wagner, CC; Allen, JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
Swedish Environmental Protection Agency. (2017). [Rapport till Naturvårdsverkets hälsorelaterade miljöövervakning: Utvärdering av samband mellan mammors POP-belastning under graviditets-och amningsperioden och deras barns hälsa]. (2215-17-008).
Sweeney, MF; Hasan, N; Soto, AM; Sonnenschein, C. (2015). Environmental endocrine disruptors: Effects on the human male reproductive system [Review]. Rev Endocr Metab Disord 16: 341–357. 10.1007/s11154-016-9337-4.26847433
Takagi, A; Sai, K; Umemura, T; Hasegawa, R; Kurokawa, Y. (1991). Short-term exposure to the peroxisome proliferators, perfluorooctanoic acid and perfluorodecanoic acid, causes significant increase of 8-hydroxydeoxyguanosine in liver DNA of rats. Cancer Lett 57: 55–60. 10.1016/0304-3835(91)90063-N.2025879
Takagi, A; Sai, K; Umemura, T; Hasegawa, R; Kurokawa, Y. (1992). Hepatomegaly is an early biomarker for hepatocarcinogenesis induced by peroxisome proliferators. J Environ Pathol Toxicol Oncol 11: 145–149.1625184
Thankamony, A; Pasterski, V; Ong, KK; Acerini, CL; Hughes, IA. (2016). Anogenital distance as a marker of androgen exposure in humans. Andrology 0: 1–10. 10.1111/andr.12156.
Thomsen, ML; Henriksen, LS; Tinggaard, J; Nielsen, F; Jensen, TK; Main, KM. (2021). Associations between exposure to perfluoroalkyl substances and body fat evaluated by DXA and MRI in 109 adolescent boys. Environ Health 20: 73. 10.1186/s12940-021-00758-3.34187491
Tian, Y; Liang, H; Miao, M; Yang, F; Ji, H; Cao, W; Liu, X; Zhang, X; Chen, A; Xiao, H; Hu, H; Yuan, W. (2019). Maternal plasma concentrations of perfluoroalkyl and polyfluoroalkyl substances during pregnancy and anogenital distance in male infants. Hum Reprod 34: 1356–1368. 10.1093/humrep/dez058.31242507
Tian, Y; Miao, M; Ji, H; Zhang, X; Chen, A; Wang, Z; Yuan, W; Liang, H. (2021). Prenatal exposure to perfluoroalkyl substances and cord plasma lipid concentrations. Environ Pollut 268: 115426. 10.1016/j.envpol.2020.115426.33152632
Timmermann, CA; Budtz-Jørgensen, E; Jensen, TK; Osuna, CE; Petersen, MS; Steuerwald, U; Nielsen, F; Poulsen, LK; Weihe, P; Grandjean, P. (2017a). Association between perfluoroalkyl substance exposure and asthma and allergic disease in children as modified by MMR vaccination. J Immunotoxicol 14: 39–49. 10.1080/1547691X.2016.1254306.28091126
Timmermann, CA; Budtz-Jørgensen, E; Petersen, MS; Weihe, P; Steuerwald, U; Nielsen, F; Jensen, TK; Grandjean, P. (2017b). Shorter duration of breastfeeding at elevated exposures to perfluoroalkyl substances. Reprod Toxicol 68: 164–170. 10.1016/j.reprotox.2016.07.010.27421579
Timmermann, CAG; Andersen, MS; Budtz-Jørgensen, E; Boye, H; Nielsen, F; Jensen, RC; Bruun, S; Husby, S; Grandjean, P; Jensen, TK. (2022). Pregnancy exposure to perfluoroalkyl substances and associations with prolactin concentrations and breastfeeding in the Odense Child Cohort. J Clin Endocrinol Metab 107: e631–e642. 10.1210/clinem/dgab638.34529060
Timmermann, CAG; Pedersen, HS; Weihe, P; Bjerregaard, P; Nielsen, F; Heilmann, C; Grandjean, P. (2021). Concentrations of tetanus and diphtheria antibodies in vaccinated Greenlandic children aged 7-12 years exposed to marine pollutants, a cross sectional study. Environ Res 203: 111712. 10.1016/j.envres.2021.111712.34343554
Toor, JM; Sikka, SC. (2017). Developmental and reproductive disorders: Role of endocrine disruptors in testicular toxicity. In Gupta RC (Ed.), Reproductive and developmental toxicology (2nd ed., pp. 1111–1121). San Diego, CA: Academic Press. 10.1016/B978-0-12-804239-7.00059-7.
Tropp, J; Markus, EJ. (2001). Effects of mild food deprivation on the estrous cycle of rats. Physiol Behav 73: 553–559. 10.1016/s0031-9384(01)00487-5.11495659
Truong, L; Rericha, Y; Thunga, P; Marvel, S; Wallis, D; Simonich, MT; Field, JA; Cao, D; Reif, DM; Tanguay, RL. (2022). Systematic developmental toxicity assessment of a structurally diverse library of PFAS in zebrafish. J Hazard Mater 431: 128615. 10.1016/j.jhazmat.2022.128615.35263707
Tsai, MS; Chang, SH; Kuo, WH; Kuo, CH; Li, SY; Wang, MY; Chang, DY; Lu, YS; Huang, CS; Cheng, AL; Lin, CH; Chen, PC. (2020). A case-control study of perfluoroalkyl substances and the risk of breast cancer in Taiwanese women. Environ Int 142: 105850. 10.1016/j.envint.2020.105850.32580117
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996a). Guidelines for reproductive toxicity risk assessment [EPA Report]. (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30004YQB.txt.
U.S. EPA (U.S. Environmental Protection Agency). (1996b). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1998). Health effects test guidelines OPPTS 870.7800 immunotoxicity. (EPA 712-C-98-351). Washington, DC: Prevention, Pesticides and Toxic Substances, U.S. Environmental Protection Agency. http://www.epa.gov/ocspp/pubs/frs/publications/Test_Guidelines/series870.htm.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2003). Toxicological review of methyl ethyl ketone (CAS No. 78-93-3): In support of summary information on the Integrated Risk Information System (IRIS). (EPA 635/R-03/009). Washington, DC. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0071tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2004). Toxicological review of boron and compounds. In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/04/052). Washington, DC: U.S. Environmental Protection Agency, IRIS. http://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P1006CK9.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Toxicological review of tetrahydrofuran. In support of summary information on the integrated risk information system (IRIS) (pp. 1–207). (EPA/635/R-11/006F). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2014). Guidance for applying quantitative data to develop data-derived extrapolation factors for interspecies and intraspecies extrapolation [EPA Report]. (EPA/100/R-14/002F). Washington, DC: Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2015-01/documents/ddef-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16-002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfos_hesd_final_508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16-003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoa_hesd_final-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016c). The Third Unregulated Contaminant Monitoring Rule. Available online at https://www.epa.gov/dwucmr/third-unregulated-contaminant-monitoring-rule (accessed
U.S. EPA (U.S. Environmental Protection Agency). (2018). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) (public comment draft). (EPA-823-R-18-307). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2019a). ChemView [Database]. Retrieved from https://chemview.epa.gov/chemview
U.S. EPA (U.S. Environmental Protection Agency). (2019b). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2019c). Development of the Proposed Unregulated Contaminant Monitoring Rule for the Fifth Monitoring Cycle (UCMR 5): Public Meeting and Webinar Held July 16, 2019. (815A19001). https://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100XWUH.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). CompTox Chemicals Dashboard [Bioactivity] [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2022b). Review of EPA’s analyses to support EPA’s national primary drinking water rulemaking for PFAS. (EPA-SAB-22-008). https://sab.epa.gov/ords/sab/f?p=100:18:16490947993:::18:P18_ID:2601.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). Review of EPA’s Analysis to Support EPA’s National Primary Drinking Water Rulemaking for PFAS. (EPA-SAB-22-008). U.S. Environmental Protection Agency, Science Advisory Board.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). Final Human health toxicity assessment for perfluorooctane sulfonic acid (PFOS) and related salts [EPA Report]. Washington, DC: Environmental Protection Agency, U.S., Office of Water, Health and Ecological Criteria Division.
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Final human health toxicity assessment for perfluorooctanoic acid (PFOA) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
U.S. EPA (U.S. Environmental Protection Agency). (2024c). Framework for estimating noncancer health risks associated with mixtures of per- and polyfluoroalkyl substances (PFAS). (EPA-815-R-24-003). Washington, DC. www.epa.gov/system/files/documents/2024-04/final-pfas-mix-framework-3.25.24_final-508.pdf.
Ulhaq, M; Carlsson, G; örn, S; Norrgren, L. (2013). Comparison of developmental toxicity of seven perfluoroalkyl acids to zebrafish embryos. Environ Toxicol Pharmacol 36: 423–426. 10.1016/j.etap.2013.05.004.23770452
Unkila, M; Pohjanvirta, R; Tuomisto, J. (1992). Acute toxicity of perfluorodecanoic acid and cobalt protoporphyrin in a TCDD-sensitive and a TCDD-resistant rat strain. Chemosphere 25: 1233–1238. 10.1016/0045-6535(92)90135-E.
Valenti, L,. Pelusi, S.,. Bianco, C.,. Ceriotti, F.,. Berzuini, A.,. Iogna Prat, L.,. Trotti, R.,. Malvestiti, F.,. D'Ambrosio, R.,. Lampertico, P.,. Colli, A.,. Colombo, M.,. Tsochatzis, E.,. A. Fraquelli, M.,. Prati, D.,. (2021). Definition of Healthy Ranges for Alanine Aminotransferase Levels: A 2021 Update. Hematology 5: 1824–1832. 10.1002/hep4.1794.
Valvi, D; Højlund, K; Coull, BA; Nielsen, F; Weihe, P; Grandjean, P. (2021). Life-course Exposure to Perfluoroalkyl Substances in Relation to Markers of Glucose Homeostasis in Early Adulthood. J Clin Endocrinol Metab 106: 2495–2504. 10.1210/clinem/dgab267.33890111
Valvi, D; Oulhote, Y; Weihe, P; Dalgård, C; Bjerve, KS; Steuerwald, U; Grandjean, P. (2017). Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107: 205–215. 10.1016/j.envint.2017.07.016.28753482
Van Anders, SM; Watson, NV. (2006). Menstrual cycle irregularities are associated with testosterone levels in healthy premenopausal women. Am J Hum Biol 18: 841–844. 10.1002/ajhb.20555.17039468
van Kerkhof, LWM; Van Dycke, KCG; Jansen, EHJ, M; Beekhof, PK; van Oostrom, CTM; Ruskovska, T; Velickova, N; Kamcev, N; Pennings, JLA; van Steeg, H; Rodenburg, W. (2015). Diurnal variation of hormonal and lipid biomarkers in a molecular epidemiology-like setting. PLoS ONE 10: e0135652. 10.1371/journal.pone.0135652.26285127
Van Rafelghem, MJ; Andersen, ME. (1988). The effects of perfluorodecanoic acid on hepatic stearoyl-coenzyme A desaturase and mixed function oxidase activities in rats. Fundam Appl Toxicol 11: 503–510. 10.1016/0272-0590(88)90114-5.2906022
Van Rafelghem, MJ; Inhorn, SL; Peterson, RE. (1987a). Effects of perfluorodecanoic acid on thyroid status in rats. Toxicol Appl Pharmacol 87: 430–439. 10.1016/0041-008X(87)90248-1.3564018
Van Rafelghem, MJ; Mattie, DR; Bruner, RH; Andersen, ME. (1987b). Pathological and hepatic ultrastructural effects of a single dose of perfluoro-n-decanoic acid in the rat, hamster, mouse, and guinea pig. Fundam Appl Toxicol 9: 522–540. 10.1016/0272-0590(87)90034-0.3692011
Van Rafelghem, MJ; Noren, CW; Menahan, LA; Peterson, RE. (1988a). Interrelationships between energy and fat metabolism and hypophagia in rats treated with perfluorodecanoic acid. Toxicol Lett 40: 57–69. 10.1016/0378-4274(88)90183-X.3124303
Van Rafelghem, MJ; Vanden Heuvel, JP; Menahan, LA; Peterson, RE. (1988b). Perfluorodecanoic acid and lipid metabolism in the rat. Lipids 23: 671–678. 10.1007/BF02535666.3419281
Vanden Heuvel, JP; Kuslikis, BI; Peterson, RE. (1992). Covalent binding of perfluorinated fatty acids to proteins in the plasma, liver and testes of rats. Chem Biol Interact 82: 317–328. 10.1016/0009-2797(92)90003-4.1606626
Vanden Heuvel, JP; Kuslikis, BI; Van Rafelghem, MJ; Peterson, RE. (1991). Disposition of perfluorodecanoic acid in male and female rats. Toxicol Appl Pharmacol 107: 450–459. 10.1016/0041-008X(91)90308-2.2000633
Varshavsky, JR; Robinson, JF; Zhou, Y; Puckett, KA; Kwan, E; Buarpung, S; Aburajab, R; Gaw, SL; Sen, S; Gao, SM; Smith, SC; Park, JS; Zakharevich, I; Gerona, RR; Fisher, SJ; Woodruff, TJ. (2021). Organophosphate flame retardants, highly fluorinated chemicals, and biomarkers of placental development and disease during mid-gestation. Toxicol Sci 181: 215–228. 10.1093/toxsci/kfab028.33677611
Vasilenko, P; Adams, WC; Frieden, EH. (1981). Uterine size and glycogen-content in cycling and pregnant rats - Influence of relaxin. Biol Reprod 25: 162–169. 10.1095/biolreprod25.1.162.7197174
Velarde, MC; Chan, AFO; Sajo, MEJ, V; Zakharevich, I; Melamed, J; Uy, GLB; Teves, JMY; Corachea, AJM; Valparaiso, AP; Macalindong, SS; Cabaluna, ND; Dofitas, RB; Giudice, LC; Gerona, RR. (2022). Elevated levels of perfluoroalkyl substances in breast cancer patients within the Greater Manila Area. Chemosphere 286 Pt 1: 131545. 10.1016/j.chemosphere.2021.131545.34293563
Verner, MA; Longnecker, MP. (2015). Comment on “enhanced elimination of perfluorooctanesulfonic acid by menstruating women: evidence from population-based pharmacokinetic modeling" [Letter]. Environ Sci Technol 49: 5836–5837. 10.1021/acs.est.5b00187.25871968
Vestergaard, S; Nielsen, F; Andersson, AM; Hjøllund, NH; Grandjean, P; Andersen, HR; Jensen, TK. (2012). Association between perfluorinated compounds and time to pregnancy in a prospective cohort of Danish couples attempting to conceive. Hum Reprod 27: 873–880. 10.1093/humrep/der450.22246448
Vuong, A; Yolton, K; Webster, GM; Sjodin, A; Calafat, AM; Braun, JM; Dietrich, K; Lanphear, BP; Chen, A. (2016). Prenatal polybrominated diphenyl ether and perfluoroalkyl substance exposures and executive function in school-age children. Environ Res 147: 556–564. 10.1016/j.envres.2016.01.008.26832761
Vuong, AM; Yolton, K; Wang, Z; Xie, C; Webster, GM; Ye, X; Calafat, AM; Braun, JM; Dietrich, KN; Lanphear, BP; Chen, A. (2018). Childhood perfluoroalkyl substance exposure and executive function in children at 8 years. Environ Int 119: 212–219. 10.1016/j.envint.2018.06.028.29980044
Wahlang, B; Beier, JI; Clair, HB; Bellis-Jones, HJ; Falkner, K; Mcclain, CJ; Cave, MC. (2013). Toxicant-associated steatohepatitis [Review]. Toxicol Pathol 41: 343–360. 10.1177/0192623312468517.23262638
Walaas, O. (1952). Effect of oestrogens on the glycogen content of the rat uterus. European Journal of Endocrinology 10: 175–192. 10.1530/acta.0.0100175.
Wan, HT; Mruk, DD; Wong, CK; Cheng, CY. (2013). Targeting testis-specific proteins to inhibit spermatogenesis: lesson from endocrine disrupting chemicals [Review]. Expert Opin Ther Targets 17: 839–855. 10.1517/14728222.2013.791679.23600530
Wang, B; Fu, J; Gao, K; Liu, Q; Zhuang, L; Zhang, G; Long, M; Na, J; Ren, M; Wang, A; Liang, R; Shen, G; Li, Z; Lu, Q. (2021). Early pregnancy loss: Do Per- and polyfluoroalkyl substances matter? Int, Environ 157: 106837. 10.1016/j.envint.2021.106837.
Wang, B; Zhang, R; Jin, F; Lou, H; Mao, Y; Zhu, W; Zhou, W; Zhang, P; Zhang, J. (2017). Perfluoroalkyl substances and endometriosis-related infertility in Chinese women. Environ Int 102: 207–212. 10.1016/j.envint.2017.03.003.28283302
Wang, D; Gao, Q; Wang, T; Kan, Z; Li, X; Hu, L; Peng, CY; Qian, F; Wang, Y; Granato, D. (2020). Green tea polyphenols and epigallocatechin-3-gallate protect against perfluorodecanoic acid induced liver damage and inflammation in mice by inhibiting NLRP3 inflammasome activation. Food Res Int 127: 108628. 10.1016/j.foodres.2019.108628.31882076
Wang, J; Pan, Y; Cui, Q; Yao, B; Wang, J; Dai, J. (2018a). Penetration of PFASs across the blood cerebrospinal fluid barrier and its determinants in humans. Environ Sci Technol 52: 13553–13561. 10.1021/acs.est.8b04550.30362723
Wang, J; Zeng, XW; Bloom, MS; Qian, Z; Hinyard, LJ; Belue, R; Lin, S; Wang, SQ; Tian, YP; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Dong, GH. (2019). Renal function and isomers of perfluorooctanoate (PFOA) and perfluorooctanesulfonate (PFOS): Isomers of C8 Health Project in China. Chemosphere 218: 1042–1049. 10.1016/j.chemosphere.2018.11.191.30609483
Wang, Y; Adgent, M; Su, PH; Chen, HY; Chen, PC; Hsiung, CA; Wang, SL. (2016). Prenatal exposure to perfluorocarboxylic acids (PFCAs) and fetal and postnatal growth in the Taiwan maternal and infant cohort study. Environ Health Perspect 124: 1794–1800. 10.1289/ehp.1509998.26895313
Wang, Y; Rogan, WJ; Chen, HY; Chen, PC; Su, PH; Chen, HY; Wang, SL. (2015). Prenatal exposure to perfluroalkyl substances and children's IQ: The Taiwan maternal and infant cohort study. Int J Hyg Environ Health 218: 639–644. 10.1016/j.ijheh.2015.07.002.26205657
Wang, Y; Rogan, WJ; Chen, PC; Lien, GW; Chen, HY; Tseng, YC; Longnecker, MP; Wang, SL. (2014a). Association between maternal serum perfluoroalkyl substances during pregnancy and maternal and cord thyroid hormones: Taiwan maternal and infant cohort study. Environ Health Perspect 122: 529–534. 10.1289/ehp.1306925.24577800
Wang, Y; Starling, AP; Haug, LS; Eggesbo, M; Becher, G; Thomsen, C; Travlos, G; King, D; Hoppin, JA; Rogan, WJ; Longnecker, MP. (2013). Association between perfluoroalkyl substances and thyroid stimulating hormone among pregnant women: a cross-sectional study. Environ Health 12: 76. 10.1186/1476-069X-12-76.24010716
Wang, Y; Zhang, L; Teng, Y; Zhang, J; Yang, L; Li, J; Lai, J; Zhao, Y; Wu, Y. (2018b). Association of serum levels of perfluoroalkyl substances with gestational diabetes mellitus and postpartum blood glucose. J Environ Sci 69: 5–11. 10.1016/j.jes.2018.03.016.
Wang, Z; Cousins, IT; Scheringer, M; Buck, RC; Hungerbühler, K. (2014b). Global emission inventories for C4-C14 perfluoroalkyl carboxylic acid (PFCA) homologues from 1951 to 2030, Part I: production and emissions from quantifiable sources [Review]. Environ Int 70: 62–75. 10.1016/j.envint.2014.04.013.24932785
Wang, Z; Shi, R; Ding, G; Yao, Q; Pan, C; Gao, Y; Tian, Y. (2022). Association between maternal serum concentration of perfluoroalkyl substances (PFASs) at delivery and acute infectious diseases in infancy. Chemosphere 289: 133235. 10.1016/j.chemosphere.2021.133235.34896425
Washington, JW; Yoo, H; Ellington, JJ; Jenkins, TM; Libelo, EL. (2010). Concentrations, distribution, and persistence of perfluoroalkylates in sludge-applied soils near Decatur, Alabama, USA. Environ Sci Technol 44: 8390–8396. 10.1021/es1003846.20949951
Watkins, DJ; Josson, J; Elston, B; Bartell, SM; Shin, HM; Vieira, VM; Savitz, DA; Fletcher, T; Wellenius, GA. (2013). Exposure to perfluoroalkyl acids and markers of kidney function among children and adolescents living near a chemical plant. Environ Health Perspect 121: 625–630. 10.1289/ehp.1205838.23482063
Weaver, YM; Ehresman, DJ; Butenhoff, JL; Hagenbuch, B. (2010). Roles of rat renal organic anion transporters in transporting perfluorinated carboxylates with different chain lengths. Sci, Toxicol 113: 305–314. 10.1093/toxsci/kfp275.
Weisskopf, MG; Seals, RM; Webster, TF. (2018). Bias amplification in epidemiologic analysis of exposure to mixtures. Environ Health Perspect 126. 10.1289/EHP2450.
Westwood, FR. (2008). The female rat reproductive cycle: A practical histological guide to staging [Review]. Toxicol Pathol 36: 375–384. 10.1177/0192623308315665.18441260
Whalan, JE. (2015). A toxicologist's guide to clinical pathology in animals: Hematology, clinical chemistry, urinalysis. Switzerland: Springer International Publishing. 10.1007/978-3-319-15853-2.
Whitworth, KW; Haug, LS; Baird, DD; Becher, G; Hoppin, JA; Skjaerven, R; Thomsen, C; Eggesbo, M; Travlos, G; Wilson, R; Longnecker, MP. (2012). Perfluorinated compounds and subfecundity in pregnant women. Epidemiology 23: 257–263. 10.1097/EDE.0b013e31823b5031.22081060
WHO (World Health Organization). (2010). WHO laboratory manual for the examination and processing of human semen. In WHO laboratory manual for the examination and processing of human semen (5th ed.). Geneva, Switzerland.
Wielsøe, M; Kern, P; Bonefeld-Jørgensen, EC. (2017). Serum levels of environmental pollutants is a risk factor for breast cancer in Inuit: a case control study. Environ Health 16: 56. 10.1186/s12940-017-0269-6.28610584
Wikström, S; Hussein, G; Lingroth Karlsson, A; Lindh, CH; Bornehag, CG. (2021). Exposure to perfluoroalkyl substances in early pregnancy and risk of sporadic first trimester miscarriage. Sci Rep 11: 3568. 10.1038/s41598-021-82748-6.33574373
Wikström, S; Lin, PI; Lindh, CH; Shu, H; Bornehag, CG. (2020). Maternal serum levels of perfluoroalkyl substances in early pregnancy and offspring birth weight. Pediatr Res 87: 1093–1099. 10.1038/s41390-019-0720-1.31835271
Wilson, MW; Lay, LT; Chow, CK; Tai, HH; Robertson, LW; Glauert, HP. (1995). Altered hepatic eicosanoid concentrations in rats treated with the peroxisome proliferators ciprofibrate and perfluorodecanoic acid. Arch Toxicol 69: 491–497. 10.1007/s002040050203.8526745
Wilson, VS; Blystone, CR; Hotchkiss, AK; Rider, CV; Gray, LE Jr. (2008). Diverse mechanisms of anti-androgen action: Impact on male rat reproductive tract development [Review]. Int J Androl 31: 178–187. 10.1111/j.1365-2605.2007.00861.x.18315717
Wise, LA; Wesselink, AK; Schildroth, S; Calafat, AM; Bethea, TN; Geller, RJ; Coleman, CM; Fruh, V; Claus Henn, B; Botelho, JC; Harmon, QE; Thirkill, M; Wegienka, GR; Baird, DD. (2022). Correlates of plasma concentrations of per- and poly-fluoroalkyl substances among reproductive-aged Black women. Environ Res 203: 111860. 10.1016/j.envres.2021.111860.34403666
Wolf, CJ; Schmid, JE; Lau, C; Abbott, BD. (2012). Activation of mouse and human peroxisome proliferator-activated receptor-alpha (PPARα) by perfluoroalkyl acids (PFAAs): further investigation of C4-C12 compounds. Reprod Toxicol 33: 546–551. 10.1016/j.reprotox.2011.09.009.22107727
Wolf, CJ; Takacs, ML; Schmid, JE; Lau, C; Abbott, BD. (2008). Activation of mouse and human peroxisome proliferator-activated receptor alpha by perfluoroalkyl acids of different functional groups and chain lengths. Toxicol Sci 106: 162–171. 10.1093/toxsci/kfn166.18713766
Wong, F; Macleod, M; Mueller, JF; Cousins, IT. (2014). Enhanced elimination of perfluorooctane sulfonic acid by menstruating women: evidence from population-based pharmacokinetic modeling. Environ Sci Technol 48: 8807–8814. 10.1021/es500796y.24943117
Woods, MM; Lanphear, BP; Braun, JM; McCandless, LC. (2017). Gestational exposure to endocrine disrupting chemicals in relation to infant birth weight: A Bayesian analysis of the HOME Study. Environ Health 16: 115. 10.1186/s12940-017-0332-3.29078782
Workman, CE; Becker, AB; Azad, MB; Moraes, TJ; Mandhane, PJ; Turvey, SE; Subbarao, P; Brook, JR; Sears, MR; Wong, CS. (2019). Associations between concentrations of perfluoroalkyl substances in human plasma and maternal, infant, and home characteristics in Winnipeg, Canada. Environ Pollut 249: 758–766. 10.1016/j.envpol.2019.03.054.30933773
Xiao, C; Grandjean, P; Valvi, D; Nielsen, F; Jensen, TK; Weihe, P; Oulhote, Y. (2019). Associations of exposure to perfluoroalkyl substances with thyroid hormone concentrations and birth size. J Clin Endocrinol Metab 105: 735–745. 10.1210/clinem/dgz147.
Xie, X; Feng, LP; Weng, XQ; Liu, S; Chen, JM; Guo, XR; Gao, XY; Fei, QY; Hao, G; Jing, CX. (2021). Perfluoroalkyl and polyfluoroalkyl substance exposure and association with sex hormone concentrations: Results from the NHANES 2015-2016. Environ Sci Eur 33: 69. 10.1186/s12302-021-00508-9.36061407
Xu, C; Yin, S; Liu, Y; Chen, F; Zhong, Z; Li, F; Liu, K; Liu, W. (2019a). Prenatal exposure to chlorinated polyfluoroalkyl ether sulfonic acids and perfluoroalkyl acids: Potential role of maternal determinants and associations with birth outcomes. J Hazard Mater 380: 120867. 10.1016/j.jhazmat.2019.120867.31330388
Xu, M; Zhang, T; Lv, C; Niu, Q; Zong, W; Tang, J; Liu, R. (2019b). Perfluorodecanoic acid-induced oxidative stress and DNA damage investigated at the cellular and molecular levels. Ecotoxicol Environ Saf 185: 109699. 10.1016/j.ecoenv.2019.109699.31561076
Yamada, A; Bemrah, N; Veyrand, B; Pollono, C; Merlo, M; Desvignes, V; Sirot, V; Marchand, P; Berrebi, A; Cariou, R; Antignac, JP; Le Bizec, B; Leblanc, JC. (2014). Dietary exposure to perfluoroalkyl acids of specific French adult sub-populations: High seafood consumers, high freshwater fish consumers and pregnant women. Sci Total Environ 491-492: 170–175. 10.1016/j.scitotenv.2014.01.089.24530183
Yamamoto, A; Kawashima, Y. (1997). Perfluorodecanoic acid enhances the formation of oleic acid in rat liver. Biochem J 325 (Pt 2): 429–434. 10.1042/bj3250429.9230124
Yang, BY; Wu, J; Niu, XL; He, CJ; Bloom, MS; Abudoukade, M; Abulizi, M; Xu, AM; Li, BB; Li, L; Zhong, XM; Wu, QZ; Chu, C; Luo, YN; Liu, XX; Zeng, XW; Yu, YJ; Dong, GH; Zou, XG; Liu, T. (2022a). Low-level environmental per- and polyfluoroalkyl substances and preterm birth: A nested case-control study among a Uyghur population in northwestern China. Exposure and Health 14: 793–805. 10.1007/s12403-021-00454-0.
Yang, J; Wang, H; Du, H; Fang, H; Han, M; Wang, Y; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2022b). Exposure to perfluoroalkyl substances was associated with estrogen homeostasis in pregnant women. Sci Total Environ 805: 150360. 10.1016/j.scitotenv.2021.150360.34818773
Yang, J; Wang, H; Du, H; Fang, H; Han, M; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2020). Serum perfluoroalkyl substances in relation to lipid metabolism in Chinese pregnant women. Chemosphere 273: 128566. 10.1016/j.chemosphere.2020.128566.33097232
Yang, L; Li, J; Lai, J; Luan, H; Cai, Z; Wang, Y; Zhao, Y; Wu, Y. (2016a). Placental transfer of perfluoroalkyl substances and associations with thyroid hormones: Beijing prenatal exposure study. Sci Rep 6: 21699. 10.1038/srep21699.26898235
Yang, L; Wang, Z; Shi, Y; Li, J; Wang, Y; Zhao, Y; Wu, Y; Cai, Z. (2016b). Human placental transfer of perfluoroalkyl acid precursors: Levels and profiles in paired maternal and cord serum. Chemosphere 144: 1631–1638. 10.1016/j.chemosphere.2015.10.063.26517392
Yang, Q; Guo, X; Sun, P; Chen, Y; Zhang, W; Gao, A. (2018). Association of serum levels of perfluoroalkyl substances (PFASs) with the metabolic syndrome (MetS) in Chinese male adults: A cross-sectional study. Sci Total Environ 621: 1542–1549. 10.1016/j.scitotenv.2017.10.074.29054655
Yao, J; Dong, Z; Jiang, L; Pan, Y; Zhao, M; Bai, X; Dai, J. (2023). Emerging and Legacy Perfluoroalkyl Substances in Breastfed Chinese Infants: Renal Clearance, Body Burden, and Implications. Environ Health Perspect 131: 37003–37003. 10.1289/EHP11403.36862174
Yao, J; Pan, Y; Sheng, N; Su, Z; Guo, Y; Wang, J; Dai, J. (2020). Novel perfluoroalkyl ether carboxylic acids (PFECAs) and sulfonic acids (PFESAs): Occurrence and association with serum biochemical parameters in residents living near a fluorochemical plant in China. Environ Sci Technol 54: 13389–13398. 10.1021/acs.est.0c02888.33047597
Yao, Q; Gao, Y; Zhang, Y; Qin, K; Liew, Z; Tian, Y. (2021). Associations of paternal and maternal per- and polyfluoroalkyl substances exposure with cord serum reproductive hormones, placental steroidogenic enzyme and birth weight. Chemosphere 285: 131521. 10.1016/j.chemosphere.2021.131521.34273704
Yao, Q; Shi, R; Wang, C; Han, W; Gao, Y; Zhang, Y; Zhou, Y; Ding, G; Tian, Y. (2019). Cord blood per- and polyfluoroalkyl substances, placental steroidogenic enzyme, and cord blood reproductive hormone. Environ Int 129: 573–582. 10.1016/j.envint.2019.03.047.31174145
Yao, Q; Vinturache, A; Lei, X; Wang, Z; Pan, C; Shi, R; Yuan, T; Gao, Y; Tian, Y. (2022). Prenatal exposure to per- and polyfluoroalkyl substances, fetal thyroid hormones, and infant neurodevelopment. Environ Res 206: 112561. 10.1016/j.envres.2021.112561.34954147
Yeung, LW; Guruge, KS; Taniyasu, S; Yamashita, N; Angus, PW; Herath, CB. (2013). Profiles of perfluoroalkyl substances in the liver and serum of patients with liver cancer and cirrhosis in Australia. Ecotoxicol Environ Saf 96: 139–146. 10.1016/j.ecoenv.2013.06.006.23849467
Ylinen, M; Auriola, S. (1990). Tissue distribution and elimination of perfluorodecanoic acid in the rat after single intraperitoneal administration. Pharmacol Toxicol 66: 45–48. 10.1111/j.1600-0773.1990.tb00700.x.
Yoo, H; Washington, JW; Jenkins, TM; Ellington, JJ. (2011). Quantitative determination of perfluorochemicals and fluorotelomer alcohols in plants from biosolid-amended fields using LC/MS/MS and GC/MS. Environ Sci Technol 45: 7985–7990. 10.1021/es102972m.21247105
Yu, G; Jin, M; Huang, Y; Aimuzi, R; Zheng, T; Nian, M; Tian, Y; Wang, W; Luo, Z; Shen, L; Wang, X; Du, Q; Xu, W; Zhang, J. (2021). Environmental exposure to perfluoroalkyl substances in early pregnancy, maternal glucose homeostasis and the risk of gestational diabetes: A prospective cohort study. Environ Int 156: 106621. 10.1016/j.envint.2021.106621.33984575
Zeng, X; Chen, Q; Zhang, X; Li, H; Liu, Q; Li, C; Ma, M; Zhang, J; Zhang, W; Zhang, J; Huang, L. (2019a). Association between prenatal exposure to perfluoroalkyl substances and asthma-related diseases in preschool children. Environ Sci Pollut Res Int 26: 29639–29648. 10.1007/s11356-019-05864-x.31399834
Zeng, XW; Bloom, MS; Dharmage, SC; Lodge, CJ; Chen, D; Li, S; Guo, Y; Roponen, M; Jalava, P; Hirvonen, MR; Ma, H; Hao, YT; Chen, W; Yang, M; Chu, C; Li, QQ; Hu, LW; Liu, KK; Yang, BY; Liu, S; Fu, C; Dong, GH. (2019b). Prenatal exposure to perfluoroalkyl substances is associated with lower hand, foot and mouth disease viruses antibody response in infancy: Findings from the Guangzhou Birth Cohort Study. Sci Total Environ 663: 60–67. 10.1016/j.scitotenv.2019.01.325.30708217
Zeng, XW; Lodge, CJ; Dharmage, SC; Bloom, MS; Yu, Y; Yang, M; Chu, C; Li, QQ; Hu, LW; Liu, KK; Yang, BY; Dong, GH. (2019c). Isomers of per- and polyfluoroalkyl substances and uric acid in adults: Isomers of C8 Health Project in China. Environ Int 133: 105160. 10.1016/j.envint.2019.105160.31518937
Zeng, XW; Qian, Z; Emo, B; Vaughn, M; Bao, J; Qin, XD; Zhu, Y; Li, J; Lee, YL; Dong, GH. (2015). Association of polyfluoroalkyl chemical exposure with serum lipids in children. Sci Total Environ 512-513: 364–370. 10.1016/j.scitotenv.2015.01.042.25638651
Zhang, C; Sundaram, R; Maisog, J; Calafat, AM; Barr, DB; Buck Louis, GM. (2015). A prospective study of prepregnancy serum concentrations of perfluorochemicals and the risk of gestational diabetes. Fertil Steril 103: 184–189. 10.1016/j.fertnstert.2014.10.001.25450302
Zhang, R; Ye, J; Wei, Q; Li, M; Xu, K; Li, Z; Lin, W; Liu, P; Chen, R; Ma, A; Zhou, Z. (2018a). Plasma concentration of 14 perfluoroalkyl acids (PFAAs) among children from seven cities in Guangdong, China. Sci Total Environ 616-617: 1469–1476. 10.1016/j.scitotenv.2017.10.167.29066194
Zhang, S; Tan, R; Pan, R; Xiong, J; Tian, Y; Wu, J; Chen, L. (2018b). Association of perfluoroalkyl and polyfluoroalkyl substances with premature ovarian insufficiency in Chinese women. J Clin Endocrinol Metab 103: 2543–2551. 10.1210/jc.2017-02783.29986037
Zhang, T; Sun, H; Lin, Y; Qin, X; Zhang, Y; Geng, X; Kannan, K. (2013a). Distribution of poly- and perfluoroalkyl substances in matched samples from pregnant women and carbon chain length related maternal transfer. Environ Sci Technol 47: 7974–7981. 10.1021/es400937y.23777259
Zhang, T; Zhang, B; Bai, X; Yao, Y; Wang, L; Shu, Y; Kannan, K; Huang, X; Sun, H. (2019). Health status of elderly people living near e-waste recycling sites: association of e-waste dismantling activities with legacy perfluoroalkyl substances (PFASs). Environ Sci Technol Lett 6: 133–140. 10.1021/acs.estlett.9b00085.
Zhang, Y; Beesoon, S; Zhu, L; Martin, JW. (2013b). Biomonitoring of perfluoroalkyl acids in human urine and estimates of biological half-life. Environ Sci Technol 47: 10619–10627. 10.1021/es401905e.23980546
Zhang, Y; Pan, C; Ren, Y; Wang, Z; Luo, J; Ding, G; Vinturache, A; Wang, X; Shi, R; Ouyang, F; Zhang, J; Li, J; Gao, Y; Tian, Y. (2022). Association of maternal exposure to perfluoroalkyl and polyfluroalkyl substances with infant growth from birth to 12 months: A prospective cohort study. Sci Total Environ 806: 151303. 10.1016/j.scitotenv.2021.151303.34749968
Zhang, YM; Dong, XY; Fan, LJ; Zhang, ZL; Wang, Q; Jiang, N; Yang, XS. (2017). Poly- and perfluorinated compounds activate human pregnane × receptor. Toxicology 380: 23–29. 10.1016/j.tox.2017.01.012.28115241
Zhao, W; Cui, R; Wang, J; Dai, J. (2017). Inhibition effects of perfluoroalkyl acids on progesterone production in mLTC-1. J Environ Sci 56: 272–280. 10.1016/j.jes.2016.08.026.
Zhao, Y; Jin, H; Qu, J; Zhang, S; Hu, S; Xue, J; Zhao, M. (2022). The influences of perfluoroalkyl substances on the rheumatoid arthritis clinic. BMC Immunol 23: 10. 10.1186/s12865-022-00483-7.35246023
Zhou, W; Zhang, L; Tong, C; Fang, F; Zhao, S; Tian, Y; Tao, Y; Zhang, J. (2017a). Plasma perfluoroalkyl and polyfluoroalkyl substances concentration and menstrual cycle characteristics in preconception women. Environ Health Perspect 125: 067012. 10.1289/EHP1203.28657892
Zhou, Y; Hu, LW; Qian, ZM; Chang, JJ; King, C; Paul, G; Lin, S; Chen, PC; Lee, YL; Dong, GH. (2016). Association of perfluoroalkyl substances exposure with reproductive hormone levels in adolescents: By sex status. Environ Int 94: 189–195. 10.1016/j.envint.2016.05.018.27258660
Zhou, Y; Hu, LW; Qian, ZM; Geiger, SD; Parrish, KL; Dharmage, SC; Campbell, B; Roponen, M; Jalava, P; Hirvonen, MR; Heinrich, J; Zeng, XW; Yang, BY; Qin, XD; Lee, YL; Dong, GH. (2017b). Interaction effects of polyfluoroalkyl substances and sex steroid hormones on asthma among children. Sci Rep 7: 899. 10.1038/s41598-017-01140-5.28420867
Zhu, Y; Qin, XD; Zeng, XW; Paul, G; Morawska, L; Su, MW; Tsai, CH; Wang, SQ; Lee, YL; Dong, GH. (2016). Associations of serum perfluoroalkyl acid levels with T-helper cell-specific cytokines in children: By gender and asthma status. Sci Total Environ 559: 166–173. 10.1016/j.scitotenv.2016.03.187.27060656