# AUTHORS | CONTRIBUTORS | REVIEWERS

## Assessment Managers (Lead Authors)

J. Phillip Kaiser (https://orcid.org/0009-0002-6371-4142), Ph.D.; Lucina Lizarraga (https://orcid.org/0000-0001-5395-9192?lang=en), Ph.D. | EPA/ORD/CPHEA

## Authors

Xabier Arzuaga (https://orcid.org/0000-0002-7978-5431), Ph.D.; Thomas F. Bateson (https://orcid.org/0000-0003-1355-5745), Sc.D., M.P.H.; J. Allen Davis (https://orcid.org/0000-0002-3238-3849), M.S.P.H.; Andrew Kraft (https://orcid.org/0000-0003-3630-6741), Ph.D.; Elizabeth Radke (https://orcid.org/0000-0002-2504-2405), Ph.D.; Hongyu Ru (https://orcid.org/0000-0002-4324-8984), Ph.D.; Paul Schlosser (https://orcid.org/0000-0002-9699-9108), Ph.D.; J. Michael Wright (https://orcid.org/0000-0001-6813-9760), Sc.D. | EPA/ORD/CPHEA

## Contributors

Michelle M. Angrish (https://orcid.org/0000-0002-4956-4806), Ph.D.; Krista Christensen (https://orcid.org/0000-0003-4431-336X), M.P.H., Ph.D.; Michael Dzierlenga (https://orcid.org/0000-0001-7010-6191), Ph.D.; Ingrid Druwe (https://orcid.org/0000-0002-0591-0295), Ph.D.; Barbara Glenn, Ph.D. (retired); Andrew Hotchkiss, Ph.D.; Stephanie Kim, Ph.D.; Christopher Lau, Ph.D.; Geniece M. Lehman (https://orcid.org/0000-0002-7172-4175), Ph.D.; Susan Makris (https://orcid.org/0000-0003-1358-7384), M.S. (retired); Anuradha Mudipalli, Ph.D.; Kathleen Newhouse (https://orcid.org/0000-0002-7193-0876), M.S.; Kristen Rappazzo, Ph.D.; Tammy Stoker, Ph.D.; Andre Weaver, Ph.D.; Erin Yost (https://orcid.org/0000-0001-8615-9204), Ph.D.; Jay Zhao (https://orcid.org/0000-0001-7600-8840), Ph.D. | EPA/ORD/CPHEA
Chris Corton, Ph.D.; Jason C. Lambert, Ph.D. | EPA/ORD/CCTE
April Luke, M.S. | EPA/OLEM
Andrew A Rooney, Ph.D.; Kyla Taylor, Ph.D.; Dori Germolec, Ph.D. | DTT/NIEHS
Nora Abdel-Gawad (former); Alexis Agbai; Angela Scafidi (former); Rebecca Schaefer | Oak Ridge Associated Universities (ORAU) Contractor
Robyn B. Blain, Ph.D.; Alexandra E. Goldstone, M.P.H.; Alexander J. Lindahl, M.P.H.; Christopher A. Sibrizzi, M.P.H. | ICF

## Production Team

Ryan Jones (HERO Director); Jack Rehmann (CPHEA Webmaster); Dahnish Shams (Project Management Team); Avanti Shirke (Project Management Team); Jessica Soto-Hernandez (Project Management Team); Samuel Thacker (HERO Team); Garland Waleko (Project Management Team) | EPA/ORD/CPHEA

## Executive Direction

Wayne Cascio, M.D. (CPHEA Director); V. Kay Holt, M.S. (CPHEA Deputy Director); Samantha Jones, Ph.D. (CPHEA Associate Director); Jon Jeffery Sutton, MBA (CPHEA POS Director); Kristina Thayer, Ph.D. (CPAD Director); Andrew Kraft, Ph.D. (IRIS PFAS Team Lead and CPAD Associate Director); Paul White, Ph.D. (CPAD Senior Science Advisor); Ravi Subramanian, Ph.D. (CPAD Senior Science Advisor); Elizabeth Radke, Ph.D. (Branch Chief); Janice Lee, Ph.D. (Branch Chief); Viktor Morozov, Ph.D. (Branch Chief); Shannon Hanna, Ph.D. (Branch Chief); Glenn Rice, Ph.D. (Branch Chief); Vicki Soto, B.S. (Branch Chief) | EPA/ORD/CPHEA

## Reviewers

CPAD Executive Review Committee
Kristina Thayer | CPAD Division Director
Paul White | CPAD Senior Science Advisor
Glenn Rice | CPHEA/CPAD/TEAB-C Branch Chief
Karen Hogan | CPHEA/CPAD/Emeritus
Alan Stern | NJDEP (retired), Contractor

### Agency Reviewers

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of the Administrator/Office of Children's Health Protection
  Office of Air and Radiation/Office of Air Quality Planning and Standards
  Office of Chemical Safety and Pollution Prevention
  Office of Land and Emergency Management
  Office of Water
  Region 2, New York City, NY
  Region 8, Denver, CO

### Interagency Reviewers

This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). Comments were submitted by:

- The White House
  - Office of Science and Technology Policy
  Office of Management and Budget
  Department of Defense
  Department of Agriculture
  Department of Health and Human Services
  Agency for Toxic Substances and Disease Registry
  National Institute of Environmental Health Sciences
  - National Institute of Occupational Safety and Health