# 5 DERIVATION OF TOXICITY VALUES

## 5.1 NONCANCER AND CANCER HEALTH EFFECT CATEGORIES CONSIDERED

The available evidence indicates that oral exposure to perfluorodecanoic acid (PFDA) is likely to cause adverse hepatic, immune, developmental, and male and female reproductive effects in humans given sufficient exposure conditions, on the basis of findings from epidemiological and animal toxicity studies. This section aims to characterize the dose levels associated with these identified hazards and derive toxicity values as presented below. Additionally, the available evidence suggests PFDA exposure might have the potential to cause cardiometabolic and neurodevelopmental effects in humans given sufficient PFDA exposure conditions, on the basis of findings from a limited number of epidemiological studies; the results are considered too uncertain, however, to support the derivation of toxicity values. For all other health effects (i.e., endocrine, urinary, hematology, special senses [eye and harderian gland], dermal and musculoskeletal systems), the evidence is inadequate to assess the hazard potential; therefore, these endpoints were not considered for the derivation of toxicity values.

There are no available studies to inform the potential for PFDA to cause adverse health effects via inhalation exposure, therefore, the derivation of reference concentrations (RfCs) is precluded (see Section 5.2.4). Likewise, evidence pertaining to the evaluation of carcinogenicity was considered inadequate to assess carcinogenic potential of PFDA in humans, precluding the derivation of cancer toxicity values via any exposure route (see Section 5.3).

## 5.2 NONCANCER TOXICITY VALUES

The noncancer toxicity values (i.e., oral reference doses [RfDs]) derived in this section are estimates of an exposure for a given duration to the human population (including susceptible subgroups and/or lifestages) that are likely to be without an appreciable risk of adverse health effects (see Section 1.2.1). The RfD derived in Section 5.2.1 corresponds to chronic, lifetime exposure. In addition, a less-than-lifetime toxicity value (referred to as a “subchronic RfD”) is derived in Section 5.2.3. This subchronic RfD can be useful for certain decision purposes (e.g., site-specific risk assessments with less-than-lifetime exposures). Both the lifetime and subchronic RfD include organ/system-specific RfDs (osRfDs) associated with each health effect considered for point-of-departure (POD) derivation, as supported by the available data. These toxicity values might be useful in some contexts (e.g., when assessing the potential cumulative effects of multiple chemical exposures occurring simultaneously). Section 5.2.4 summarizes the conclusion that no information exists to inform the potential toxicity of inhaled PFDA or to derive an inhalation RfC.

### 5.2.1 Oral Reference Dose (RfD) Derivation

#### Study/Endpoint Selection

Data sufficient to support dose-response analyses for oral PFDA exposure were available for all identified human health hazards (see Section 4.1): hepatic, immune, developmental, and male and female reproductive effects. Rationales for study selection and the specifics of RfD calculations, as well as the determination of confidence in quantitative estimates are detailed in this section.

The following general considerations were used to prioritize studies for estimating PODs for potential use in toxicity value derivation. Dependent on the evidence for each identified hazard, high or medium confidence human studies that were deemed influential to the hazard conclusions and suitable for dose-response analysis were prioritized for POD derivation and compared with PODs derived from animal data when possible. Human studies were available for developmental and immunotoxicity effects. For other health effects (i.e., hepatic, and male and female reproductive effects), only evidence from animal studies was considered influential for hazard identification; therefore, these data were prioritized for dose-response assessment. Given the lack of comprehensive subchronic or chronic animal studies, medium and high confidence short-term studies in animals of longer exposure duration (e.g., 28 days versus 7 or 14 days) and with exposure levels near the lower dose range of doses tested across the evidence base were preferred along with medium or high confidence animal studies evaluating exposure during development. These types of medium and high confidence human and animal studies increase the confidence in the resultant RfD because they represent data with lower risk of bias and reduce the need for low-dose and exposure duration extrapolation (see Appendix C).

A summary of endpoints and rationales considered for toxicity value derivation is presented below.

#### Hepatic Effects

The hazard conclusions for PFDA-induced liver effects are based primarily on moderate evidence from short-term animal studies (see Section 3.2.1). In humans, an association between PFDA exposure and ALT levels in the blood was identified, but there was considerable uncertainty due to potential for confounding by other PFAS. As such, only animal studies were considered for dose-response analysis. The database of animal studies examining liver effects includes several short-term studies in rats and mice (Wang et al., 2020; Frawley et al., 2018; NTP, 2018; Yamamoto and Kawashima, 1997; Kawashima et al., 1995; Permadi et al., 1993; Takagi et al., 1992, 1991; Harris and Birnbaum, 1989). In particular, two high confidence studies in SD rats gavaged with PFDA for 28-days were prioritized for the derivation of candidate values because they included several hepatic endpoints that together provided coherent evidence of liver toxicity with PFDA exposure across histopathology, organ weights and/or clinical chemistry (Frawley et al., 2018; NTP, 2018) (see Table 5-1). Additionally, these studies had the longest exposure duration (28 days) and examined the lower range of PFDA doses (dose range of observed effects is 0.156–2.5 mg/kg-day) across the available studies examining hepatic effects.

PFDA induced changes in serum liver biomarkers, hepatocyte lesions and increased liver weights in rats across the two 28-day studies (Frawley et al., 2018; NTP, 2018). Although some of the individual changes have the potential to represent adaptive responses (e.g., increased liver weights and hypertrophy), the constellation of coherent liver effects, most notably consistent effects across multiple serum biomarkers of hepatocyte and biliary injury and histological findings of structural hepatocyte degeneration (necrosis), provide clear evidence of adversity (see “Consideration for potentially adaptive versus adverse responses" under Section 3.2.1 for more details). Alterations in the levels of serum enzymes such as ALT, AST, and ALP and other functional biomarkers (bile salt/acids, bilirubin, and blood proteins [albumin, globulin, and total protein]) were reported in the 28-day study that evaluated clinical chemistry (NTP, 2018). Increases in AST and ALP levels were consistent across sexes and dose groups and generally occurred at lower doses that did not induce significant body weight changes or other general systemic effects (0.156–0.625 mg/kg-day PFDA). Similarly, dose-related increases in relative liver weights were reported in male and female rats at ≥0.125 mg/kg-day across the two 28-day studies (Frawley et al., 2018; NTP, 2018). As discussed in Section 3.2.1, relative liver weight is generally preferred over absolute liver weight; as information on the former was available, changes in absolute liver weight were not considered for dose-response analyses. Given there is no clear indication of sex-specific differences in sensitivity with respect to PFDA-induced liver effects in the available animal toxicity studies, data for both male and female SD rats for these endpoints were advanced for dose-response modeling.

Corroborative hepatocyte lesions such as cytoplastic alterations and vacuolization, hypertrophy and necrosis were reported in rats at higher doses (≥0.625 mg/kg-day) across the two 28-day studies prioritized for dose-response analysis (Frawley et al., 2018; NTP, 2018). The histopathological observations showed a clear progression in severity across lesions and dose groups. These findings provide additional support for the adversity of the progressive effects on the liver with PFDA exposure but were not prioritized for dose-response analysis due to the presence of more sensitive liver endpoints (i.e., serum AST and ALP levels, and relative liver weight; see Table 5-1).

Table 5-1 Endpoints considered for dose-response modeling and derivation of points of departure for liver effects in animals

Endpoint | Study reference and confidence | Exposure route and duration | Test strain, species, and sex | POD derived? | Notes
Increased serum ALT | NTP (2018); high confidence | Gavage, 28 d | SD rat, male and female | No | Dose-dependent effects were only observed in females and occurred at higher doses compared with other liver findings
Increased serum AST | NTP (2018); high confidence | Gavage, 28 d | SD rat, male and female | Yes | Dose-dependent effects were consistent across sexes and concordant with liver weight and liver histopathology findings
Increased serum ALP | NTP (2018); high confidence | Gavage, 28 d | SD rat, male and female | Yes | Effects were consistent across sexes and dose groups and concordant with liver weight and liver histopathology findings.
Other serum biomarkers (increased bile salts/acids and bilirubin, and decreased albumin and globulin) | NTP (2018); high confidence | Gavage, 28 d | SD rat, male and female | No | Effects were mostly consistent across sexes but occurred at higher doses compared with other liver findings
Hepatocyte lesions | NTP (2018); high confidence (cytoplasmic alterations and vacuolization, hypertrophy, and necrosis) | Gavage, 28 d | SD rat, male and female | No | Effects were consistent across sexes and studies but occurred at higher doses compared with other liver findings
Hepatocyte lesions | Frawley et al., (2018); high confidence (necrosis) | Gavage, 28 d | SD rat, male | No | Effects were consistent across sexes and studies but occurred at higher doses compared with other liver findings
Increased relative liver weight | NTP (2018); high confidence | Gavage, 28 d | SD rat, male and female | Yes | Dose-dependent effects were consistent across studies, cohorts, sexes and were concordant with serum biomarker and liver histopathology findings. There was no reason to prioritize one dataset over the other.
Increased relative liver weight | Frawley et al., (2018); high confidence | Gavage, 28 d | SD rat, female (included three experimental cohorts) | Yes

#### Immune Effects

As described in Section 3.2.2, the strongest evidence for immune effects was from epidemiological studies that provided moderate evidence of immunosuppression (Shih et al., 2021; Timmermann et al., 2021; Grandjean et al., 2017b; Grandjean et al., 2017a; Kielsen et al., 2016; Grandjean et al., 2012); thus, this outcome was prioritized for dose-response analysis and studies of hypersensitivity (which collectively provided slight human evidence) were not considered. Given the uncertainties with the animal data described in Section 3.2.2 (e.g., influence of systemic toxicity), only the human data were considered for the derivation of PODs.

The two medium confidence epidemiological studies of antibody response following vaccination providing the primary support for the hazard judgment were conducted in different birth cohorts of the Faroe Islands population (see Table 3-11). These studies include measures of PFDA exposure taken perinatally (pregnancy week 32 to 2 weeks postpartum); at 18 months; and at 5, 7, and 13 years and measures of antibody levels at 5, 7, and 13 years for both diphtheria and tetanus. The relevant etiologic window of exposure for this outcome is not known. Although there were some heterogeneous results (see Section 3.2.2), the direction of association across these combinations of different timings of exposure and outcome measurement were generally consistent, indicating immunosuppression (i.e., decreased antibody response with higher exposure). However, selecting the most informative exposure-outcome combination(s) for POD derivation is complicated by the lack of a clear etiologic window. In a follow-up publication without new data, the study authors performed benchmark dose modeling for a subset of the data presented in Grandjean et al., (2012), specifically antibody levels at age 7 and PFDA concentrations at age 5, and antibody levels at age 5 (prebooster) and perinatal PFDA concentrations (Budtz-Jørgensen and Grandjean, 2018b). These were selected by the authors due to the strong inverse associations observed and the results were considered reasonably representative of the study results overall. After review of the BMD methods and additional modeling details (Budtz-Jørgensen and Grandjean, 2018b) for completeness and appropriateness (see Appendix C.1.1), EPA used the authors’ analytic regression results for this Toxicological Review (see Table 5-2).

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFDA measured at age 5 years, against log2-transformed antitetanus antibody concentrations measured at the 7-year-old examination controlling for sex, exact age at the 7-year-old examination, and booster type at age 5 years. Three model shapes of PFDA were evaluated by Budtz-Jøorgensen and Grandjean (2018a): a linear model, a piecewise-linear model with a knot at the median, and a logarithmic function. Tables 5-3 and Table 5-4 shows the best fitting model results of PFDA and tetanus from this analysis of the combination of the Faroe cohort born in 1997–2000 Grandjean et al., (2012) with the cohort born in 2007–2009 (Grandjean et al., 2017b). These results differ from those shown separately for the two cohorts in Section 3.2 because the PFDA exposure has not been log2-transformed (only the antibody concentrations have). The published results from the “log-log" models in which both exposure and outcome are log-transformed (Grandjean et al., 2017b; Grandjean et al., 2012) are not statistically suited to derive points of departure for toxicity values, whereas the untransformed PFDA exposure models are suited to do so Budtz-Jørgensen and Grandjean (2018a).

The regression model used to estimate the results in Table 5-3 and Table 5-4 were from “single-PFAS models" in which only one PFAS exposure (here, PFDA) was included and “multi-PFAS models, " which were parallel models fit with control of PFOA and PFOA. Two-time windows of exposure and outcome were evaluated: PFDA exposure measured at age 5 years with tetanus antibodies measured at age 7 years; and PFDA measured perinatally, and tetanus antibodies measured at age 5 years. The details of the regression analyses were provided to EPA by the authors and are available in (Budtz-Jørgensen and Grandjean, 2018b). Detailed interpretations of these results with discussion of potential confounding are provided in Appendix C.1.1 in which these results are used to estimate benchmark doses (BMDs) and lower bound benchmark doses (BMDLs), which identify point of departures for reference doses.

Table 5-2 Endpoints considered for dose-response modeling and derivation of points of departure for immune effects in humans

Endpoint | Study reference and confidence | POD derived? | Notes
Antibody concentrations for diphtheria and tetanus | Grandjean et al. (2012) [Birth cohort 1997–2000 with follow-up to age 7] and (Grandjean et al., 2017a) [Birth cohort 1997–2000 with follow-up to age 13]; Grandjean et al. (2017b) [Birth cohorts from 1997–2000 and 2007–2009 with follow-up to age 5]; medium confidence | No | Effect was generally coherent with epidemiological evidence for other antibody effects. However, while these results contribute to understanding the hazard for PFDA, the analytic models in these specific publications used log-transformed exposure and log-transformed outcome variables and such log-log models cannot be used for BMD calculations and thus PODs were not derived.
Antibody concentrations for diphtheria and tetanus | Budtz-Jørgensen and Grandjean (2018a); Birth cohorts 1997–2000 and 2007–2009 using different analyses of combined data from Grandjean et al. (2012) and Grandjean et al. (2017a) medium confidence | Yes | Effect generally coherent with epidemiological evidence for other antibody effects. Results were based on analytic models using log-transformed outcome and untransformed exposure, which were suitable for BMD calculations and POD derivations (see Appendix C.1.1 for more details on BMD modeling results).

Table 5-3 Results from the analyses of PFDA measured in serum at age 5 years (and measured perinatally) and log2(tetanus antibody concentrations) measured at ages 5 and 7 years in a single-PFAS models and multi-PFAS models from (Budtz-Jørgensen and Grandjean, 2018a, b)

Exposure | Outcome | Model shape (best fit) | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum^a^ | 95% CI^b^ | Slope (β) fit | 95% One-sided lower bound slope (βLB) per ng/mL in serum^c^
PFDA at age 5 yr | Tetanus antibodies at age 7 yr | Linear | No | −1.55 | (−2.73, −0.370) | p = 0.01 | −2.55
PFDA at age 5 yr | Tetanus antibodies at age 7 yr | Linear | Yes | −0.98 | (−2.31, 0.355) | p = 0.15 | −2.10
Perinatal PFDA | Tetanus antibodies at age 5 yr | Linear | No | −0.343 | (−1.25, 0.563) | p = 0.46 | −1.10
Perinatal PFDA | Tetanus antibodies at age 5 yr | Linear | Yes | −0.038 | (−1.12,1.05) | p = 0.95 | −0.874

a This slope is used to estimate the benchmark dose (BMD). See Appendix C.1.1.

b EPA computed the 95% CI from the β and SE(β) provided in (Budtz-Jørgensen and Grandjean, 2018b).

c This slope is used to estimate the lower bound benchmark dose (BMDL). See Appendix C.1.1.

Table 5-4 Results from the analyses of PFDA measured in serum at age 5 years (and measured perinatally) and log2(diphtheria antibody concentrations) measured at ages 5 and 7 years in a single-PFAS models and multi-PFAS model from (Budtz-Jørgensen and Grandjean, 2018b)

Exposure | Outcome | Model shape (best fit) | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum^a^ | 95% CI^b^ | Slope (β) fit | 95% One-sided lower bound slope (βLB) per ng/mL in serum^c^
PFDA at age 5 yr | Diphtheria antibodies at age 7 yr | Linear | No | −0.894 | (−1.99, 0.206) | p = 0.11 | −1.82
PFDA at age 5 yr | Diphtheria antibodies at age 7 yr | Linear | Yes | −0.297 | (−1.54, 0.948) | p = 0.64 | −1.35
Perinatal PFDA | Diphtheria antibodies at age 5 yr | Piecewise Linear | No | −3.70 | (−8.11, 0.708) | p = 0.10 | −7.40
Perinatal PFDA | Diphtheria antibodies at age 5 yr | Piecewise Linear | Yes | −2.47 | (−3.94, −1.00) | p = 0.001 | −3.70

a This slope is used to estimate the benchmark dose (BMD). See Appendix C.1.1.

b EPA computed the 95% CI from the β and SE(β) provided in (Budtz-Jørgensen and Grandjean, 2018b).

c This slope is used to estimate the lower bound benchmark dose (BMDL). See Appendix C.1.1.

#### Developmental Effects

Uncertainties in the human evidence of developmental effects resulted in a judgment of slight (see Section 3.2.3); however, the database includes several well-conducted medium and high confidence epidemiological studies reporting birth weight deficits of varying magnitude in male or female neonates or both. Birth weight deficits (and several other developmental endpoints) were generally larger and more consistent among studies that sampled maternal serum later in pregnancy including postpartum measures. This observation suggests that those samples may be most prone to potential bias from changing pregnancy hemodynamics, but the complex patterns of influence due to pregnancy hemodynamics are not completely understood. Nevertheless, the apparent influence of pregnancy hemodynamics introduces considerable uncertainty in the interpretation of these associations of PFDA-induced developmental effects and was a major contributing factor in the overall evidence integration judgment for this health effect (see Section 3.2.3). Despite these concerns regarding sample timing, decreased birth weight was the focus of dose-response analysis, given the accuracy in measurement of the endpoint, and the abundance of high-quality studies. There is considerably less uncertainty related to pregnancy hemodynamics in studies based on maternal serum samples collected during the first trimester.

Twenty-eight epidemiological studies (8 high and 10 medium confidence) evaluated associations between PFDA and fetal growth restriction, including 26 studies examining mean birth weight. Given the abundance of high confidence studies, low and medium confidence studies were not considered for POD derivation; thus, four high confidence studies were considered as they provided consistent evidence of associations within the overall population and across both sexes. Among the eight high confidence studies detailed in Table 5-5, two studies Buck Louis et al. (2018); Bach et al. (2016) were not considered further, as they did not find evidence of an inverse association between PFDA exposures and mean birth weight in the overall population. Two studies were not advanced because they reported vastly different findings across the sexes Lind et al. (2017a); Wang et al. (2016) with no clear biological explanation for this inconsistency (see discussion in Section 3.2.3).

Three of the four remaining studies examined PFDA during the third trimester Luo et al. (2021); Yao et al. (2021); Valvi et al. (2017) and one examined PFDA across the first and second trimesters (Wikström et al., 2020). Two high confidence studies, Valvi et al. (2017) and Wikström et al. (2020), were selected for dose-response quantification. In the (Wikström et al., 2020) study, 96% of samples were collected during the first trimester and the remaining during the early weeks of the second trimester; sensitivity analyses showed no differences when second trimester samples were excluded. The Valvi et al. (2017) has a unique design that may increase study sensitivity by sampling all participants during the same gestational week (i.e., 34). These two studies had a low overall risk of bias and reliable exposure measurements with sufficient exposure contrasts (PFDA median/interquartile ranges: 0.26/0.15 and 0.28/0.16 ng/mL, respectively for Wikström et al. (2020); Valvi et al. (2017) and other characteristics that allowed for adequate study sensitivity to detect associations (see Table 5-5), As noted above, the Valvi et al., (2017) and Wikström et al. (2020) studies selected for dose-response quantification reported results consistent in magnitude that allowed the consideration of sex-specific and overall population results. A limitation of the Valvi et al. (2017) study advancing to dose response is that it did not have early trimester samples (third trimester only) and may be prone to some potential bias due to pregnancy hemodynamics (see more details in Appendix F). Despite these important concerns regarding sample timing, as noted above, derivation of a POD(s) for developmental outcomes using the Valvi, 2017 study was considered potentially informative to toxicity value derivation for birth weight effects reported by (Wikström et al., 2020).

The one available high confidence animal study that examined developmental toxicity in mice treated with PFDA (Harris and Birnbaum, 1989) provided moderate evidence of developmental toxicity (see Section 3.2.3). Several endpoints from this study were considered suitable for POD derivation (see Table 5-6) and for comparison to PODs derived from the human studies. Harris and Birnbaum (1989) reported developmental effects in C57BL/6N mice treated either on GD 10–13 (0–32 mg/kg-day) or GD 6–15 (0–12.8 mg/kg-day). Harris and Birnbaum (1989) reported statistically significant changes for increased % resorptions per litter and decreased number of live fetuses GD 6–15 component of the study. However, these effects were not considered for dose-response analysis because their interpretation is confounded by overt maternal toxicity (i.e., mortality) observed at the same dose. Statistically significant and dose-dependent decreases in fetal body weight were also observed in both the GD 10–13 and the GD 6–15 experiments. Data for decreased fetal body weight from the GD 6–15 experiment were prioritized for dose-response analysis over data from the GD 10–13 experiment, since the former experiment encompasses a larger developmental window. Statistically significant and dose-dependent increases in variations (i.e., delayed braincase and phalanges ossification and absence of fifth sternebrae) were also reported, but there were methodological concerns and uncertainty regarding the adversity of these endpoints (see Section 3.2.3) that precluded their consideration for dose-response analysis.

Table 5-5 Mean birth weight deficit studies considered for dose-response modeling and derivation of points of departure for developmental effects in humans

Study reference and confidence | Population-overall population, sex-specific and all births vs. term births only | PFDA biomarker sample timing | POD derived? | Notes
Valvi et al., (2017); high confidence | Overall population; sex-specific; all births | Trimester 3 | Yes | Effect was large in magnitude and coherent with findings in mice and epidemiological evidence for other biologically related effects (e.g., decreased postnatal growth and birth length).
Wikström et al. (2020), high confidence | Overall population; sex-specific; all births | Trimesters 1–2 (94% in T1) | Yes | Effect was statistically significant, large in magnitude, and coherent with findings in mice and epidemiological evidence for other biologically related effects (e.g., decreased postnatal growth and birth length).
Luo et al., (2021), high confidence | Overall population; term births | Trimester 3 | No | Effect size was statistically significant and moderate in magnitude. Results are coherent with findings in mice and epidemiological evidence for other biologically related effects (e.g., preterm birth, postnatal growth, and other fetal growth measures such as birth length).
Yao et al. (2021), high confidence | Overall population; sex-specific; all births | Trimester 3 | No | Effect size was moderate in magnitude. Results are coherent with findings in mice and epidemiological evidence for other biologically related effects (e.g., preterm birth, postnatal growth, and other fetal growth measures such as birth length).
Wang et al. (2016); high confidence | Sex-specific; term births | Trimester 3 | No | Study reported sex-specific findings that were not consistent across male and female neonates.
Bach et al. (2016); high confidence | Sex-specific; term births | Trimester 1 | No | Study reported sex-specific findings that were not consistent across male and female neonates.
Buck Louis et al. (2018), high confidence | Overall population; term births | Trimester 2 | No | Study did not detect inverse associations between mean birth weight and PFDA.
Lind et al. (2017a), high confidence | Sex-specific; all births | Trimester 1 | No | Study reported sex-specific findings that were not consistent across male and female neonates.

Table 5-6 Endpoints considered for dose-response modeling and derivation of points of departure for developmental effects in animals

Endpoint | Study reference and confidence | Exposure route and duration | Test strain, species, and sex | POD derived? | Notes
Increased % resorptions per litter | Harris and Birnbaum (1989); high confidence | Gavage, GD 6–15 | C57BL/6N mouse, male and female | No | Effect was observed at the same dose as significant maternal mortality.
Decreased live fetuses per litter | Harris and Birnbaum (1989); high confidence | Gavage, GD 6–15 | C57BL/6N mouse, male and female | No | Effect was observed at the same dose as significant maternal mortality.
Decreased fetal body weight | Harris and Birnbaum (1989); medium confidence | Gavage, GD 10–13 | C57BL/6N mouse, male and female | No | Fetal body weight data from GD 10–13 was not advanced in lieu of the more sensitive data available from GD 6–15.
Decreased fetal body weight | Harris and Birnbaum (1989); medium confidence | Gavage, GD 6–15 | C57BL/6N mouse, male and female | Yes | Effect displayed a dose-response trend and was coherent with other developmental changes in mice and humans.
Skeletal variations (i.e., delayed braincase ossification; absence of fifth sternebrae; delayed phalanges ossification) | Harris and Birnbaum (1989); high confidence | Gavage, GD 6–15 | C57BL/6N mouse, male and female | No | The adversity and interpretation of these effects is unclear (see Section 3.2.3).

#### Male Reproductive Effects

The hazard conclusions for PFDA-induced male reproductive effects are driven by moderate evidence from a single, high confidence study in rats gavaged for 28 days (NTP, 2018). The available evidence from human studies was indeterminate (see Section 3.2.4); thus, these human studies were not considered further for POD derivation.

The single, 28-days study in adult male rats examining reproductive effects was considered low confidence for sperm evaluations based on potential reduced sensitivity due to inadequate exposure duration. Otherwise, the study would have been considered high confidence for sperm measures and was considered high confidence for other, related male reproductive endpoints. Thus, the coherent results across multiple measures, including sperm evaluations, in this well-conducted study provide support for advancing the study for dose-response modeling. Effects in male rats included significant decreases in testicular and epididymal sperm counts at doses ≥1.25 mg/kg-day (NTP, 2018). Although there are concerns about exposure sensitivity for sperm evaluations, the alterations in sperm counts are supported by concordant effects for histopathology and organ weight measures in the testis and epididymis evaluated. The decreases in absolute epididymal sperm counts (although not testicular sperm counts) displayed a dose-response gradient and thus were prioritized for POD derivation (see Table 5-7).

A consistent pattern of mild degenerative changes was detected in the testes and epididymis of exposed rats at the two highest doses (NTP, 2018). These doses were associated with significant body weight decreases (21%-38%) but concerns over potential confounding with overt systemic toxicity were mitigated by mechanistic evidence suggesting that male reproductive effects are only affected by severe changes in body weight (72%; see “Mechanistic Studies and Supplemental Information" in Section 3.2.4, Increased incidence of Leydig cell atrophy was observed at doses ≥1.25 mg/kg-day, which is consistent with reductions in spermatogenesis and serum testosterone levels reported in this same 28-day rat study and with mechanistic evidence that suggests PFDA targets Leydig cells and disrupts steroidogenesis (see “Mechanistic Studies and Supplemental Information" in Section 3.2.4). As such, this endpoint was selected for dose-response modeling (see Table 5-7), Other corroborative histopathological lesions (germinal epithelium degeneration, seminiferous tubule spermatid retention, epididymal duct germ cell exfoliation and hypospermia in the epididymis) were not advanced, as these lesions occurred mostly in the high-dose group (2.5 mg/kg-day) and had low to medium incidence rates (10%-40% compared with 0%-10% for controls). Finally, decreases in absolute testicular and epididymal weights and serum testosterone levels identified in rats were also advanced for POD derivation. Absolute weights are the preferred measure for testis and epididymis as these organs appeared to be conserved even with body weight changes (Creasy and Chapin, 2018; U.S. EPA, 1996b). The changes in organ weights and testosterone levels demonstrated a dose-response effect and were concordant with other male reproductive findings occurring at similar doses (≥1.25 mg/kg-day) (NTP, 2018).

Table 5-7 Endpoints considered for dose-response modeling and derivation of points of departure for male reproductive effects in animals

Endpoint | Study reference and confidence | Exposure route and duration | Test strain, species, and sex | POD derived? | Notes
Decreased testicular sperm counts | NTP (2018); low confidence | Gavage, 28 d | SD rat, male | No | Effects provide corroborative evidence of male reproductive toxicity but were not dose dependent.
Decreased absolute epididymis sperm counts (cauda) | NTP (2018); low confidence due to concern for potential insensitivity | Gavage, 28 d | SD rat, male | Yes | Effects displayed a dose-response pattern and were coherent with other male reproductive findings
Leydig cell atrophy | NTP (2018); high confidence | Gavage, 28 d | SD rat, male | Yes | Effects were coherent with other male reproductive findings and mechanistic evidence supporting biological plausibility
Other histopathological lesions in the testes and epididymis | NTP (2018); high confidence | Gavage, 28 d | SD rat, male | No | Effects provide corroborative evidence of male reproductive toxicity but were less sensitive compared with other findings
Decreased serum testosterone levels | NTP (2018); high confidence | Gavage, 28 d | SD rat, male | Yes | Effects displayed a dose-response pattern and were coherent with other male reproductive system findings
Decreased absolute testis weight | NTP (2018); high confidence | Gavage, 28 d | SD rat, male | Yes | Effects displayed a dose-response pattern and were coherent with other male reproductive system findings
Decreased absolute epididymis weight (cauda and whole) | NTP (2018); high confidence | Gavage, 28 d | SD rat, male | Yes | Effects displayed a dose-response pattern and were coherent with other male reproductive system findings

#### Female Reproductive Effects

The available human evidence was judged to be indeterminate and thus these data were not considered for dose-response analysis (see Section 3.2.5). Only one animal study (NTP, 2018) evaluated female reproductive effects that were due to PFDA exposure; the study was evaluated as high confidence for all endpoints examined and provided moderate evidence for female reproductive toxicity. The NTP (2018) study reported reproductive effects in female rats exposed to PFDA (doses of 0, 0.156, 0.312, 0.625, 1.25, and 2.5 mg/kg-day) via gavage for 28 days (see Table 5-8). Statistically significant dose-dependent changes were observed for the number of days spent in estrus and diestrus and for absolute and relative uterus weights; these endpoints were advanced for POD derivation. Although Bailey et al. (2004) provided guidance on the preferred measure (relative or absolute) for many organs (e.g., liver), both relative and absolute uterus weight were carried forward for POD derivation because it is unclear which is the preferred measure for this organ. Endpoints related to estrous cyclicity were also advanced for POD derivation. Under normal conditions, the estrus stage is highlighted by sexual receptivity (Goldman et al., 2007). PFDA was shown to decrease the number of days spent in estrus in female rats, which could result in decreased opportunities for mating and ultimately in reductions or delays in fertility. PFDA was also reported to cause a continuous state of diestrus (NTP, 2018). Per EPA’s Guidelines for Reproductive Toxicity Risk Assessment, “Persistent diestrus indicates temporary or permanent cessation of follicular development and ovulation, and thus at least temporary infertility.” Refer to Section 3.2.5 for a more detailed discussion. Whereas the study authors also reported increased testosterone in female rats, this effect was not considered further because its biological relevance to the development of PFDA-induced female reproductive toxicity is unclear.

Table 5-8 Endpoints considered for dose-response modeling and derivation of points of departure for female reproductive effects in animals

Endpoint | Study reference and confidence | Exposure route and duration | Test strain, species, and sex | POD derived? | Notes
Decreased estrus time | NTP (2018); high confidence | Gavage, 28 d | SD rat, female | Yes | Effect displayed a dose-response trend and was coherent with other female reproductive changes.
Increased diestrus time | NTP (2018); high confidence | Gavage, 28 d | SD rat, female | Yes | Effect displayed a dose-response trend and was coherent with other female reproductive changes.
Decreased absolute and relative uterus weight | NTP (2018); high confidence | Gavage, 28 d | SD rat, female | Yes | Effect displayed a dose-response trend and was coherent with other female reproductive changes.
Increased testosterone | NTP (2018); high confidence | Gavage, 28 d | SD rat, female | No | The toxicological significance of this effect in females for the purposes of this assessment is unclear.

#### Estimation or Selection of Points of Departure (PODs) for RfD Derivation

Consistent with EPA's Benchmark Dose Technical Guidance (U.S. EPA, 2012a), the BMD and 95% lower confidence limit on the BMD (BMDL) were estimated using a BMR selected to represent a minimal, biologically significant level of change. The BMD technical guidance (U.S. EPA, 2012a) sets up a hierarchy by which BMRs are selected, with the first and preferred approach using a biological or toxicological basis to define what minimal level of response or change is biologically significant. If that biological or toxicological information is lacking, the BMD technical guidance recommends alternative BMRs, specifically a BMR of 1 standard deviation (SD) from the control mean for continuous data or a BMR of 10% extra risk (ER) for dichotomous data (see Appendix D for more details). In cases when a biological or toxicological basis to define what minimal level of response or change is biologically significant is lacking, a BMR of less than 1 SD is also considered when there are concerns about the severity of the effect, or effects occur in a sensitive lifestage. The BMRs selected for dose-response modeling of PFDA-induced health effects are listed in Table 5-9 along with the rationale for their selection.

Table 5-9 Benchmark response levels selected for BMD modeling of PFDA health outcomes

Endpoint | BMR | Rationale
Liver effects
Increased serum enzymes in adult rats (ALT and ALP) | 1 standard deviation | No information is readily available that allows for determining a minimally biologically significant response. The Benchmark Dose Technical Guidance (U.S. EPA, 2012a) recommends a BMR based on 1 standard deviation (SD) for continuous endpoints when biological information is not sufficient to identify an appropriate BMR.
Increased relative liver weight in adult rats | 10% relative deviation | A 10% increase in liver weight is considered a minimally biologically significant response level in adult animals and has been used as the BMR for benchmark dose modeling in prior IRIS assessments.
Immune effects
Decreased antibody concentrations for diphtheria and tetanus in children | ½ standard deviation | Diphtheria and tetanus are serious and sometimes fatal infections. Immunomodulatory effects observed in children may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards. In addition, childhood represents a sensitive lifestage. Given the potential severity of this outcome, a BMR of both 1 SD and ½ SD were considered (see additional discussion in Appendix C.1.1). Ultimately, it was concluded that a BMR of ½ SD is best supported based on the severity of the outcome and the sensitive lifestage.
Developmental effects
Decreased birth weight in humans | 5% extra risk of exceeding adversity cutoff (hybrid approach) | A 5% extra risk is commonly used for dichotomous developmental endpoints as recommended by the Benchmark Dose Technical Guidance (U.S. EPA, 2012a). For birth weight, a public health definition of low birth weight (2,500 g) exists, and the hybrid approach was used to estimate the dose at which the extra risk of falling below that cutoff equaled 5% (see additional discussion in Appendix C.1.2).
Decreased fetal weight in mice | 5% relative deviation | A 5% change was used because the developmental effects were observed during a sensitive lifestage. A 5% change in markers of growth/development in gestational studies (e.g., fetal weight) is considered a minimally biologically significant response level and has been used as the BMR for benchmark dose modeling in prior IRIS assessments (U.S. EPA, 2012b, 2004, 2003).
Male reproductive effects
Increased Leydig cell atrophy in adult rats | 10% extra risk | No information is readily available that allows for determining a minimally biological significant response. A 10% ER is recommended as the standard BMR for dichotomous endpoints in the absence of information for a biologically based BMR (U.S. EPA, 2012a).
Decreased epididymal sperm counts in adult rats | 1 standard deviation | No information is readily available that allows for determining a minimally biological significant response. The Benchmark Dose Technical Guidance (U.S. EPA, 2012a) recommends a BMR based on 1 SD for continuous endpoints when biological information is not sufficient to identify an appropriate BMR.
Decreased serum testosterone in adult rats | 1 standard deviation
Decreased testicular weight in adult rats | 1 standard deviation
Decreased epididymal weight in adult rats | 1 standard deviation
Female reproductive effects
Decreased estrus time in adult rats | 5% relative deviation | Given that the PFDA-induced alterations in estrous cyclicity are possible indicators of infertility, which is an outcome of serious concern to the human population, a BMR of 5% RD is selected for these effects. Further support for the BMR of 5% RD is provided by the large magnitude of these effects. Specifically, PFDA induced a continuous state of diestrus in 100% of rats at the highest dose tested.
Increased diestrus time in adult rats | 5% relative deviation
Decreased absolute and relative uterus weight in adult rats | 1 standard deviation | No information is readily available that allows for determining a minimally biologically significant response. The Benchmark Dose Technical Guidance (U.S. EPA, 2012a) recommends a BMR based on 1 SD for continuous endpoints when biological information is not sufficient to identify an appropriate BMR.

When modeling was feasible, the estimated BMDLs were used as PODs (see Table 5-10). Further details, including the modeling output and graphical results for the model selected for each endpoint, can be found in Appendix C. When dose-response modeling was not feasible, or adequate modeling results were not obtained, no-observed-adverse-effect level (NOAEL) or lowest-observed-adverse-effect level (LOAEL) values were identified based on biological rationales when possible and used as the POD. NOAELs and LOAELs were determined based on the dose at which biologically significant changes were identified, which takes precedence over statistical significance. For example, for relative liver weight, a 10% change is generally viewed as a biologically significant level of change, taking into consideration the study-specific variability. If no biological rationale for selecting the NOAEL/LOAEL is available, statistical significance was used as the basis for selection. The PODs (based on BMD modeling or NOAEL/LOAEL selection) for the endpoints advanced for dose-response analysis are presented in Table 5-10.

#### Application of Animal-Human Pharmacokinetic Extrapolation of PFDA Toxicological Endpoints and Dosimetric Interpretation of Epidemiological Endpoints

Table 5-10 displays the POD and estimated HED PODs for liver, immune, developmental, and male and female reproductive endpoints from animal and/or human studies selected for the derivation of candidate values. Given that the available studies tested the free acid form of PFDA, normalization from a salt to the free acid using a molecular weight conversion was not performed, but formulas for providing such conversions are included in later tables.

Table 5-10 PODs considered for the derivation of PFDA candidate values

Endpoint | Study/confidence | Strain/species/sex | POD type/model | POD (mg/kg-d) | POD internal concentration^a^ (mg/L) | POD_HED_^b^ (mg/kg-d)
Liver effects
Increased AST | 28-d study (NTP, 2018); high confidence | SD rat, male | BMDL_1SD_, Hill CV | 0.123 | 3.36 | 4.93 × 10^−4^
Increased AST | 28-d study (NTP, 2018); high confidence | SD rat, female | NOAEL^c^ (1% increase) | 0.625 | 25.15 | 3.70 × 10^−3^
Increased ALP | 28-d study (NTP, 2018); high confidence | SD rat, male | NOAEL^d^ (9% increase) | 0.156 | 4.25 | 6.25 × 10^−4^
Increased ALP | 28-d study (NTP, 2018); high confidence | SD rat, female | NOAEL^c^ (14% increase) | 0.156 | 5.60 | 8.24 × 10^−4^
Increased relative liver weight | 28-d study (NTP, 2018); high confidence | SD rat, male | BMDL_10RD_, Hill CV | 0.170 | 4.90 | 7.21 × 10^−4^
Increased relative liver weight | 28-d study (NTP, 2018); high confidence | SD rat, female | BMDL_10RD_, Hill CV^(e)^ | 0.112 | 4.03 | 5.92 × 10^−4^
Increased relative liver weight | 28-d study (Frawley et al., 2018); high confidence | SD rat, female (histopathology study cohort) | BMDL_10RD_, Exp2 CV | 0.222 | 8.67 | 1.27 × 10^−3^
Increased relative liver weight | 28-d study (Frawley et al., 2018); high confidence | SD rat, female (MPS study cohort) | BMDL_10RD_, Linear CV | 0.187 | 7.04 | 1.04 × 10^−3^
Increased relative liver weight | 28-d study (Frawley et al., 2018); high confidence | SD rat, female (TDAR study cohort) | NOAEL^c^ (2% increase) | 0.125 | 4.49 | 6.61 × 10^−4^
Immune effects (developmental)
Decreased serum antitetanus antibody concentrations in children at age 7 yr and PFDA measured at age 5 yr | Budtz-Jørgensen and Grandjean (2018a); Grandjean et al. (2012); medium confidence | Human, male and female | BMDL_1/2SD_ Linear | – | 4.11 × 10^−4^ | 6.04 × 10^−8^
Decreased serum antidiphtheria antibody concentrations at age 7 yr and PFDA concentrations at age 5 yr | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | BMDL_1/2SD_ Linear | – | 4.07 × 10^−4^ | 5.98 × 10^−8^
Decreased serum antitetanus antibody concentrations at age 5 yr and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | BMDL_1/2SD_ Linear | – | 7.02 × 10^−4^ | 1.03 × 10^−7^
Decreased serum antidiphtheria antibody concentrations at age 5 yr and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | BMDL_1/2SD_ Linear | – | 2.57 × 10^−4^ | 3.78 × 10^−8^
Developmental effects
Decreased birth weight | Valvi et al. (2017); high confidence^f^ | Human, male and female | BMDL_5RD_, Hybrid | – | 2.8 × 10^−4^ | 4.12 × 10^−8^
Decreased birth weight | Valvi et al., (2017); high confidence^f^ | Human, male | BMDL_5RD_, Hybrid | – | 2.2 × 10^−4^ | 3.23 × 10^−8^
Decreased birth weight | Valvi et al., (2017); high confidence^f^ | Human, female | BMDL_5RD_, Hybrid | – | 2.4 × 10^−4^ | 3.53 × 10^−8^
| (Wikström et al., 2020); high confidence^g^ | Human, male and female^h^ | BMDL_5RD_, Hybrid | – | 3.7 × 10^−4^ | 5.44 × 10^−8^
| (Wikström et al., 2020); high confidence^g^ | Human, male | BMDL_5RD_, Hybrid | – | 3.3 × 10^−4^ | 4.85 × 10^−8^
| (Wikström et al., 2020); high confidence^g^ | Human, female | BMDL_5RD_, Hybrid | – | 3.1 × 10^−4^ | 4.56 × 10^−8^
Decreased fetal body weight | Developmental study (GD 6–15) (Harris and Birnbaum, 1989); medium confidence | C57BL/6N mouse, male and female | NOAEL^(c)^ (4% decrease) | 1 | – | 6.68 × 10^−2^
Male reproductive effects
Decreased cauda epididymis sperm count | 28-d study (NTP, 2018); low confidence | SD rat, male | BMDL_1SD_, Exp3 CV | 0.963 | 37.28 | 5.48 × 10^−3^
Increased Leydig cell atrophy | 28-d study (NTP, 2018); high confidence | SD rat, male | NOAEL^d^ (0% change) | 0.625 | 21.36 | 3.14 × 10^−3^
Decreased serum testosterone | 28-d study (NTP, 2018); high confidence | SD rat, male | NOAEL^d^ (25% decrease) | 0.625 | 21.36 | 3.14 × 10^−3^
Decreased absolute testis weight | 28-d study (NTP, 2018); high confidence | SD rat, male | BMDL_1SD_, Linear CV | 1.074 | 42.50 | 6.25 × 10^−3^
Decreased absolute cauda epididymis weight | 28-d study (NTP, 2018); high confidence | SD rat, male | BMDL_1SD_, Linear CV | 0.582 | 20.01 | 2.94 × 10^−3^
Decreased absolute whole epididymis weight | 28-d study (NTP, 2018); high confidence | SD rat, male | BMDL_1SD_, Linear NCV | 0.546 | 18.88 | 2.77 × 10^−3^
Female reproductive effects
Decreased number of days spent in estrus | 28-d study (NTP, 2018); high confidence | SD rat, female | BMDL_5RD_, Linear CV | 0.128 | 4.60 | 6.76 × 10^−4^
Increased number of days spent in diestrus | 28-d study (NTP, 2018); high confidence | SD rat, female | BMDL_5RD_, Exp2 CV | 0.200 | 7.65 | 1.12 × 10^−3^
Decreased relative uterus weight | 28-d study (NTP, 2018); high confidence | SD rat, female | NOAEL^c^ (12% increase) | 0.625 | 25.15 | 3.70 × 10^−3^
Decreased absolute uterus weight | | | NOAEL^c^ (12% increase) | 0.625 | 25.15 | 3.70 × 10^−3^

a For PODs based on rat toxicity studies, POD internal concentration (POD_int_) values were estimated by linear interpolation of the observed end-of-study serum concentrations in (NTP, 2018), as described in Section 3.1.7 and Appendix G.2.2. POD_int_ values from human epidemiological studies were determined directly from the analyses of response vs. blood concentration data.

b POD_HED_ = POD_int_ × CL_H_ for extrapolation from rat toxicity and human epidemiological studies, with CL_H_ = 0.147 mL/kg-d = 1.47 × 10⁻^4^ L/kg-d (see Table 3-3). For the developmental mouse endpoint, POD_HED_ = POD × DDEF, where DDEF = 0.067. For DDEF derivation details, see Section 3.1.7.

c No models provided adequate fit; therefore, a NOAEL approach was selected.

d After visual inspection, data were not considered amenable for BMD modeling due to obvious nonmonotonicity in the dose response; therefore, a NOAEL approach was used instead.

e Highest dose group was dropped to allow for adequate model fit.

f Trimester 3 maternal biomarker samples.

g Ninety-six percent of samples during the first trimester and the remaining during the early weeks of the second trimester; sensitivity analyses showed no differences when trimester 2 samples excluded.

h Sex-specific results were available for both males and females separately; these were consistent in magnitude with the overall result.

#### Derivation of Candidate Lifetime Toxicity Values for the RfD

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the candidate values for PFDA. The identified potential areas of susceptibility to PFDA exposure-induced health effects, including in children and possibly in women of reproductive age (see Section 4.3), can help inform uncertainty factor (UF) value selection and, subsequently, confidence in toxicity values. An explanation of these five possible areas of uncertainty and variability and the values assigned to each as a designated UF to be applied to the candidate POD_HED_ values are listed in Table 5-11 below. For liver and male and female reproductive effects, quantitative information is limited to studies in which animals were exposed for ≤28 days. Serum levels of PFDA are not predicted to reach steady state in these studies because the half-life of PFDA in rodents is longer than 28 days. Hence, continued exposure to the same dose will likely result in higher serum and tissue levels, leading to greater effects. Furthermore, for each of these identified hazards, little information is available to assess the extent to which the specific changes caused by PFDA exposure for 28 days might be expected to worsen with PFDA exposure for a lifetime, even if serum and tissue levels remained constant at the levels reached after 28 days. Separately, human equivalent PODs for these endpoints were much less sensitive (several orders of magnitude) than the PODs for developmental and immune effects from the epidemiological studies (see Table 5-10). As such, for liver, male reproductive, and female reproductive effects, derivation of candidate lifetime values was not attempted given the high degree of uncertainty associated with using PODs from a 28-day rodent study to protect against effects observed in a chronic setting. However, these endpoints were considered for the derivation of the subchronic RfD (see Section 5.2.3).

Developmental effects observed in mice from the Harris and Birnbaum (1989) study, albeit observed after exposure during a sensitive lifestage, were not considered for derivation of a candidate lifetime value. Specifically, given the availability of PODs for developmental effects from high confidence human studies that were observed to be more sensitive than the POD from the rodent study (by 6–7 orders of magnitude; see Table 5-10), the available human data were given preference. It is important to note that the (Valvi et al., 2017) study was not considered for the derivation of candidate toxicity values for developmental effects given the limitations described above. However, the PODs determined from the (Valvi et al., 2017) study are informative for the PODs and resulting RfDs for developmental effects based on birth weight data from the (Wikström et al., 2020) study.

Table 5-11 Uncertainty factors for the development of the candidate lifetime toxicity values for PFDA

UF | Value | Justification
UF_A_ | 1 | A UF_A_ of 1 is applied to developmental and immunological effects observed in humans.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability in humans in the absence of quantitative information on potential differences in pharmacokinetics and pharmacodynamics relating to PFDA exposure in humans.
UF_S_ | 1 | A UF_S_ of 1 is applied to developmental delays (i.e., decreased birth body weight) [Wikström et al. (2020); and reduced antibody responses in children Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a). The developmental period is recognized as a susceptible lifestage when exposure during a time window of development is more relevant to the induction of developmental effects than lifetime exposure in adulthood (U.S. EPA, 1991). Additional considerations for the UF_S_ for immune effects are discussed below.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is a BMDL or a NOAEL. BMDLs were available for both the developmental and immune effects in the epidemiological studies advanced for candidate value derivation.
UF_D_ | 3 | A UF_D_ of 3 is applied to account for deficiencies and uncertainties in the database. Although limited, the evidence base in laboratory animals consists of high/medium confidence short-term studies in rodents and a high confidence developmental study in mice. The database for PFDA also includes several high/medium confidence epidemiological studies most informative for immune and developmental effects, which are sensitive effects of PFDA exposure.; However, uncertainties remain regarding the lack of studies examining effects with long-term exposure in adults—including in women of reproductive age (which may have increased susceptibility), studies of potential multigenerational effects, and studies of postnatal development, neurotoxicity, and thyroid toxicity after PFDA exposure during development. In all, the data are too sparse to conclude with certainty that the quantified developmental effects are likely to be the most sensitive; thus, a UF_D_ of 1 was not selected. However, a UF_D_ of 10 was also not selected give the availability of data from well-conducted studies on a range of health outcomes in multiple species, including sensitive evaluations of developmental and immune endpoints in humans. See discussion below for additional details.
UF_C_ | See Table 5-12 | Composite Uncertainty Factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_

As described in EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) the interspecies uncertainty factor (UF_A_) is applied to account for extrapolation of animal data to humans, and accounts for uncertainty regarding the pharmacokinetic and pharmacodynamic differences across species. The datasets considered for derivation of candidate lifetime values were from human studies, so a UF_A_ = 1 was applied to all PODs after the application of dosimetric approaches for estimation of HEDs as described above.

For immune effects, both a duration extrapolation uncertainty factor (UF_s_) = 3 and a value of UF_s_ = 1 were considered to account for extrapolation from less than chronic data, ultimately selecting a UF_s_ = 1. A UF_s_ = 10 was not considered as the developmental period is recognized as a susceptible lifestage for these types of effects and therefore exposure during this time window can be considered more relevant to the induction of developmental effects than exposure in adulthood (U.S. EPA, 1991). The reduced antibody responses were measured in children 5–7 years of age. The HED calculations used for these immune effects assume chronic exposure, so an RfD based on them will assure that serum PFDA levels remain below the POD irrespective of exposure duration. Also, development is recognized as a sensitive period for effects on immune system responses. According to the WHO/IPCS Immunotoxicity Guidance for Risk Assessment, developmental immunotoxicity encompasses the prenatal, neonatal, juvenile, and adolescent lifestages and should be viewed differently from the immune system of adults from a risk assessment perspective (IPCS, 2012). Special considerations for developmental immunotoxicity include increased dose sensitivity, potential for effects to become permanent even after cessation of exposure, broader spectrum of adverse effects and “rewiring of the immune system" (IPCS, 2012), which indicates a greater health risk for early-life exposures to immunotoxicants compared with adults. Given PFDA’s long half-life and the expectation that the children and their mothers have been exposed to elevated levels of PFDA for many years, the observed effects on immune response are considered to be the result of a cumulative, prolonged exposure to the subjects from conception until the age when the response was evaluated. Further, the consequences of perturbed immune system function (in this case, suppressed antibody responses leading potentially to increased disease) during development are expected to be generally more severe and longer lasting than those that manifest in healthy adults. Taken together, the observed immune effects in children considered to be the result of prolonged exposure to PFDA and the enhanced susceptibility of the developmental immune system to chemical pollutants, attenuate concerns of potentially increased sensitivity with longer-term exposures. As such, a UF_s_ = 1 rather than a UF_s_ = 3 was applied for immune effects in children. Uncertainties regarding possible more sensitive latent effects of these impacts on the immune system during early-life exposures leading to unpredictable outcomes later in life, for example in other susceptible lifestages of reduced immunocompetence such as pregnancy and most notably old age, are addressed as part of the justification for selecting a database uncertainty factor (UFD) > 1, as discussed below.

For PFDA, both a UF_D_ = 10 and a UF_D_ = 3 were considered due to the limited database (e.g., the lack of a two-generation developmental/reproductive toxicity study) and a UF_D_ = 3 ultimately was applied. Typically, the specific study types lacking in a chemical's database that influence the value of the UF_D_ to the greatest degree are developmental toxicity and multigenerational reproductive toxicity studies. The PFDA database does include a medium confidence (Harris and Birnbaum, 1989) developmental toxicity study in mice. Despite its quality, however, that study fails to cover potential transgenerational impacts of longer-term exposures evaluated in a two-generation study. The 1994 Reference Concentration Guidance (U.S. EPA, 1994) and 2002 Reference Dose Report (U.S. EPA, 2002); (U.S. EPA, 2002) support applying a UF_D_ in situations when such a study is missing. The 2002 Reference Dose Report (U.S. EPA, 2002); (U.S. EPA, 2002) states that “[i]f the RfD/RfC is based on animal data, a factor of 3 is often applied if either a prenatal toxicity study or a two-generation reproductive study is missing.” Further, (U.S. EPA, 2002) states “[i]f the RfD/RfC is based on human data, a similar assessment regarding the completeness of the database is necessary. Information on life stages and organ systems may come from either animal or human studies. If data on specific life stages or organ systems are unavailable or limited data suggest that availability of more extensive data might decrease the POD, this should be taken into account in assigning a database UF.” Consideration of the PFDA, PFBA (a short-chain perfluoroalkyl carboxylic acid), ^27, 28^ PFBS (a short-chain perfluoroalkane sulfonic acid with a 4-carbon backbone), ^29^ PFHxA (a short-chain perfluoroalkyl carboxylic acid), and PFHxS (a long-chain perfluoroalkane sulfonic acid)^30^ databases together, however, diminish the concern that the availability of a multigenerational reproductive study would result in reference values far below those currently derived for PFDA. Although limited in their ability to assess reproductive health or function, measures of possible reproductive toxicity occurred at doses equal to or higher than those that resulted in effects in other organ systems (e.g., thyroid, liver) when measured after exposure to PFDA for 28 days (NTP, 2019). Similar results were observed for the animal databases for PFOA and PFOS indicating reproductive effects were not uniquely sensitive markers of toxicity for these long-chain PFAS (ATSDR, 2021). Further, no notable male or female reproductive effects were observed in epidemiological or toxicological studies investigating exposure to PFHxS (MDH, 2019). Therefore, considering the limited chemical-specific information alongside information gleaned from structurally related compounds, the lack of a multigenerational reproductive study is not considered a major concern relative to UF_D_ selection for PFDA.

The lone animal developmental study (Harris and Birnbaum, 1989) for PFDA also did not evaluate postnatal developmental effects. Effects on postnatal development (e.g., delayed eye opening; reduced postnatal growth) have been observed in rodents exposed to other long-chain PFAS such as PFOA (ATSDR, 2021). Overall, the available information on potential PFDA-induced postnatal developmental effects is sparse, introducing uncertainty as to whether more sensitive developmental effects of PFDA might occur and may be of concern relative to UF_D_ selection.

Another gap in the PFDA database is the lack of measures of thyroid toxicity in gestationally exposed offspring or after longer-than-28-day PFDA exposures, and the lack of a developmental neurotoxicity study. Thyroid hormones are critical in myriad physiological processes and must be maintained at sufficient levels during times of brain development in utero and after birth. Although no PFDA-specific data on thyroid hormone levels following gestational exposure are available, effects on thyroid hormone homeostasis were observed in a study in adult rats exposed to PFDA for 28 days (NTP, 2018), and disrupted thyroid signaling has been shown to be a consequence of exposure to other PFAS (U.S. EPA, 2021b). Therefore, anticipating that potentially sensitive effects that were due to PFDA exposure also could have been observed had thyroid hormone levels been measured in the Harris and Birnbaum (1989) developmental study, or in longer-term studies, is reasonable. Thus, the lack of data for PFDA-induced effects on thyroid levels in developing animals or with prolonged exposure or data on potential thyroid dependent neurodevelopmental effects is a source of uncertainty.

Lastly, the potential for sensitive effects following long-term exposure durations represents an area of uncertainty for the PFDA database. While the potential for more sensitive effects is mitigated mostly by the availability of sensitive PODs (compared with other PODs) for developmental effects from human studies, there are no comprehensive subchronic and chronic animal studies available for PFDA. The longest exposure study treated mice for 30–49 days via drinking water but tested only one high-PFDA dose (6.6 mg/kg-day) and evaluated limited endpoints (body weight and survival) (Wang et al., 2020). No chemical-specific information is available to judge the degree to which the existing endpoints in the PFDA Toxicological Review would be more sensitive with extended durations. Given that the PODs used to derive candidate values were from studies of developmental exposure, this uncertainty cannot be fully addressed through the application of a UF_s_. Specifically, for immune effects, there is a lack of epidemiological studies or studies in animals examining the effects of PFDA exposures that encompass later developmental periods (e.g., late childhood and adolescence) or other potentially susceptible lifestages such as pregnancy and old age. In addition, the available studies include limited or no evaluation of immunotoxicity categories other than immunosuppression, namely sensitization and allergic response, and autoimmunity and autoimmune disease.

Given the residual concerns for potentially more sensitive effects outlined above, a database uncertainty factor is considered necessary. Specifically, a value of 3 was selected for the UF_D_ to account for the uncertainty surrounding the lack of an evaluation of postnatal or multigenerational effects in animals, specific investigations of potential effects on thyroid function after developmental exposure or neurodevelopmental effects, and comprehensive long-term studies in multiple species.

The uncertainty factors described in Table 5-11 and the text above were applied and the resulting candidate values are shown in Table 5-12. The candidate values are derived by dividing the POD_HED_ by the composite uncertainty factor as shown below.

C a n d i d a t e v a l u e s f o r P F D A = P O D_H E D_ ÷ U F c 5-1

Table 5-12 Candidate RfD values for PFDA

Endpoint | Study/confidence | Strain/species/sex | POD_HED_ (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value (mg/kg-d)^a^
Immune effects (developmental)
Decreased serum antitetanus antibody concentration in children at age 7 yr and PFDA measured at age 5 yr | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 6.04 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased serum antidiphtheria antibody levels at age 7 yr and PFDA concentrations at age 5 yr | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 5.98 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased serum antitetanus antibody levels at age 5 y and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 1.03 × 10^−7^ | 1 | 10 | 1 | 1 | 3 | 30 | 3 × 10^−9^
Decreased serum antidiphtheria antibody levels at age 5 yr and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 3.78 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 1 × 10^−9^
Developmental effects
Decreased birth weight | (Wikström et al., 2020) high confidence | Human, male and female | 5.44 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased birth weight | (Wikström et al., 2020) high confidence | Human, male | 4.85 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
| (Wikström et al., 2020) high confidence | Human, female | 4.56 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^

a The candidate values for different salts of PFDA would be calculated by multiplying the candidate value for the free acid of PFDA by the ratio of molecular weights. For example, for the ammonium salt the ratio would be: (M W ammonium salt)/(M W free acid) = (531)/(514) = 1.033 . This same method of conversion can be applied to other salts of PFDA, such as the potassium or sodium salts, using the corresponding molecular weights.

### 5.2.2 Selection of Lifetime Toxicity Value(s)

#### Selection of Organ/System-Specific Oral Reference Doses (osRfDs)

From among the candidate values presented in Table 5-12, organ/system-specific RfDs (osRfDs) are selected for the individual organ systems identified as hazards in Section 3. The osRfD values selected were associated with decreased serum antibody concentrations in children for immune effects and decreased birth weight for developmental effects. The confidence decisions about the studies, evidence base, quantification of the POD, and overall osRfD are fully described in Table 5-13, along with the rationales for selecting those confidence levels. In deciding overall confidence, confidence in the evidence base is prioritized over the other confidence decisions. The overall confidence in the osRfD for immune effects is medium, and the confidence in the osRfD for developmental effects is medium-low. Selection of the overall RfD is described in the following section.

Table 5-13 Confidence in the organ/system-specific (osRfDs) for PFDA

Confidence categories | Designation | Discussion
Immune (developmental) osRfD = 2 × 10^−9^ mg/kg-d
Confidence in study^a^ used to derive osRfD | High | Confidence in Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a) was rated as medium primarily due to relatively limited PFDA exposure contrasts, which can decrease study sensitivity in general (HAWC link). Given that the results in this study were statistically significant and that PFOS, PFOA, and PFNA were not considered meaningful confounders (see Section 3.2.2 and Appendix C.1), EPA concluded that while there were potential study sensitivity concerns at the evaluation stage, the results clearly showed that those concerns were not borne out, and confidence in this study to derive an osRfD was judged to be high.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for immune effects is medium based on consistent findings of reduced antibody responses from two medium confidence birth cohort studies (Grandjean et al., 2012); (Grandjean et al., 2017a); (Grandjean et al., 2017b) and a low confidence study in adults (Kielsen et al., 2016). Short-term studies in animals of high/medium confidence provide supportive evidence of immunosuppression after PFDA exposure (Frawley et al., 2018); (NTP, 2018). Some residual uncertainties regarding unexplained inconsistency and potential confounding by other co-occurring PFAS from epidemiological studies and issues with concomitant overt target organ and systemic toxicity in animal studies lower confidence in the available evidence for this hazard. Other limitations include the lack of epidemiological studies or long-term/chronic studies in animals examining effects on the immune system across different developmental lifestages and immunotoxicity categories, including sensitization and allergic response and autoimmunity and autoimmune disease.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium. The POD is based on BMD modeling at the lower end of the range of the observed data and a BMDL_1/2SD_ estimate that is associated with a small degree of uncertainty due to potential confounding by PFOA (see Appendix D.1.1 for more details). The POD for decreased tetanus antibodies at age 7 yr was judged to be medium confidence based on a good model fit and was supported by the nearly identical POD for decreased diphtheria antibodies at age 7 yr. Both PODs support the osRfD. An estimate for human clearance was applied to estimate the POD_HED_ using PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on uncertainty in the pharmacokinetic modeling of PFDA above). There is also uncertainty as to the most sensitive window of vulnerability with respect to the exposure/outcome measurement timing (BMDs/BMDLs were estimated from PFDA levels measured at age 5 or perinatally and antitetanus antibody concentrations measured at age 7 or 5); (Grandjean et al., 2017b) reported that estimated PFDA “concentrations at 3 mo and 6 mo showed the strongest inverse associations with antibody concentrations at age 5 yr, particularly for tetanus.” Thus, it is possible that adverse effects during infancy could be more sensitive than between ages 5 and 7 yr.
Overall confidence in osRfD | Medium | The overall confidence in the osRfD is medium and is driven by medium confidence in the evidence base for immune effects and the quantification of the POD.
Developmental osRfD = 2 × 10^−9^ mg/kg-d
Confidence in study^a^ used to derive osRfD | Medium | Confidence in the Wikström et al. (2020) study for hazard identification was rated as high (HAWC link) for developmental effects. The study was selected for dose-response analysis due to low overall risk of bias and reliable exposure measurements, which had sufficient exposure contrasts and other characteristics that allowed for adequate study sensitivity to detect associations. The Wikström et al. (2020) study demonstrated associations consistent in magnitude for boys, girls, and the overall population. Overall, mean birth weight was considered the most precise and accurate endpoint and not anticipated to be subject to much error. This study was advanced for dose-response analysis, given minimal presumed impact of pregnancy hemodynamics given the early sampling (96% from trimester 1). Wikström et al. (2020) also adjusted for sample timing in their multivariate models and show no differences in models also restricted to trimester 1 samples only. Some uncertainty remains on the potential for confounding by other PFAS (concern primarily for PFNA), which were not examined in this study. Given the potential quantitative impact of this uncertainty, confidence in the use of this study for dose-response analysis was judged as medium rather than high.
Confidence in evidence base supporting this hazard | Medium-low | Confidence in the evidence base for developmental effects is medium. There was consistent evidence for reduced birth weight among multiple human studies, including high-quality studies. However, unlike the Wikström et al. (2020) study used here and noted above, some uncertainty remains in many studies given the predominance of associations that were detected for studies with later pregnancy sampling. The human database also showed some coherence across different measures of fetal growth restriction. In animals, the lone developmental study reported effects on fetal growth that are coherent with effects observed in humans. Some residual uncertainty regarding potential confounding by other co-occurring PFAS from epidemiological studies lowers confidence in the available evidence for this hazard.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on a BMD hybrid approach within the range of the observed data and dosimetric adjustment was based on PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on uncertainty in the pharmacokinetic modeling of PFDA above).
Overall confidence in osRfD | Medium-low | The overall confidence in the osRfD is medium-low and is driven by medium-low confidence in the evidence base for developmental effects (i.e., fetal growth restriction).

a All study evaluation details can be found on HAWC.

#### Selection of Overall Oral Reference Dose (RfD) and Confidence Statement

Organ/system-specific and overall RfD values for PFDA selected in the previous section are summarized in Table 5-14.

Table 5-14 Organ/System-specific and overall lifetime RfDs for PFDA

System | Toxicity value | Basis | POD_HED_ (mg/kg-d)^a^ | UF_C_ | osRfD or RfD (mg/kg-d) | Confidence
Immune (developmental) | osRfD | Decreased antibody concentrations for both tetanus and diphtheria in children at age 7 yr and PFDA measured at age 5 yr | 6.04 × 10^−8^ based on BMDL½ SD from Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a) | 30 | 2 × 10^−9^ | Medium
Developmental | osRfD | Decreased birth weight in males and females | 5.44 × 10^−8^ based on BMDL5%RD from (Wikström et al., 2020) | 30 | 2 × 10^−9^ | Medium-low
Immune /developmental | Overall lifetime RfD | Decreased antibody concentrations for both tetanus and diphtheria in children at age 7 yr and PFDA measured at age 5 yr Decreased birth weight in males and females | 6.04 × 10^−8^ based on BMDL½ SD from Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a) 5.44 × 10^−8^ based on BMDL5%RD from (Wikström et al., 2020) | 30 | 2 × 10^−9^ | Medium

a The details of the BMD modeling approach and results can be found in Appendix C.

From the identified human health effects of PFDA and derived osRfDs for immune and developmental effects (see Table 5-14), an overall RfD of 2 × 10^−9^ mg/kg-day based on decreased serum antibody concentrations and decreased birth weight in humans was selected. As described in Table 5-14, confidence in the RfD is medium, based on medium confidence in the immune osRfD (the developmental osRfD was medium-low confidence), noting that there was medium confidence in the quantification of the PODs for both immune (Budtz-Jørgensen and Grandjean, 2018a); (Grandjean et al., 2012) and developmental (Wikström et al., 2020) endpoints using BMD modeling. This RfD is the same for both developmental and immune critical effects given that the PODs for these two osRfDs were similar (i.e., 6.04 × 10^−8^ and 5.44 × 10^−8^, respectively) and that identical UFs were applied. Selection of the overall RfD is presumed to be protective of all other potential health effects in humans, based on the currently available evidence. Finally, the immune osRfD and developmental osRfD are based on effects observed in males and females indicating that the overall RfD would be protective for both sexes.

Overall, the immune and developmental endpoints from epidemiological studies of PFDA were preferentially advanced for the derivation of candidate lifetime values. For immune effects, osRfDs were derived for decreased serum antibody levels (for both diphtheria and tetanus) in children (male and female) at different timing of exposure and outcome measurement combinations, specifically antibody levels at age 7 and PFDA concentrations at age 5, and antibody levels at age 5 and perinatal PFDA concentrations (Budtz-Jørgensen and Grandjean, 2018a) (see Table 5-12). The toxicity value (osRfD) for immune effects of 2 × 10^−9^ mg/kg-day was based on deleterious effects observed in children showing decreased antibody concentrations for both tetanus and diphtheria at age 7 years related to serum PFDA concentrations measured at age 5 years. The PODs for decreased tetanus and diphtheria antibody concentrations were nearly identical (BMDL_1/2SD[HED]_ of 6.04 × 10^−8^ mg/kg-day for tetanus and 5.98 × 10^−8^ mg/kg-day for diphtheria) and were close to the PODs for other outcome-exposure combinations (see Table 5-10), which further supports the selected osRfD. Although both tetanus and diphtheria are rare in the U.S., the findings that PFDA exposure reduced antibody responses may be broadly indicative of developmental immunosuppression impacting overall immune function in these children. The lowest serum PFDA concentration measured at age 5 years was 0.05 ng/mL and the 10th percentile was 0.2 ng/mL (Grandjean and Bateson, 2021) so the estimated BMD_1/2SD_ (0.411 ng/mL) for this endpoint in the single-PFAS model is well within the observed range. No information was available to judge the fit of the model in the range of the BMDLs (see Appendix C.1.1 for more details).

For developmental effects, given that the candidate toxicity values are identical (see Table 5-10), the osRfD of 2 × 10^−9^ mg/kg-day [BMDL_5RD[HED]_ of 5.44 × 10^−8^ mg/kg-day) based on reduced birth weight in males and females from the Wikström et al. (2020) study was selected. Although this osRfD is not based on the lowest POD for reduced birth weight from the (Wikström et al., 2020) study, it is more representative of the general human population (males and females combined) than the comparisons in males or females only. There is some uncertainty with PODs considered from the Valvi et al. (2017) study because it is not based on early sampling and may be prone to bias from pregnancy hemodynamics to some unknown degree. As discussed in Appendix F, there is only one developmental study (Gyllenhammar et al., 2018) for PFDA that collected and was able to analyze maternal hemodynamics data such as GFR and/or albumin. This study did not report any evidence of confounding following statistical adjustment of different GFR measures for any of the PFAS examined, which is consistent with no demonstrated confounding by either GRR (Manzano-Salgado et al., 2017); (Whitworth et al., 2012) or albumin (Sagiv et al., 2018) for other PFAS examined in other studies. However, existing meta-analyses for both PFOA (Steenland et al., 2018) and PFOS (Dzierlenga et al., 2020) only detected birth weight deficits for later trimester sampling (e.g., beyond the first trimester). A similar detailed analysis was precluded for PFDA given that there are only two studies that examined any first trimester measures. Overall, there was limited evidence of any patterns of larger birth weight associations with sample timing for PFDA, but possible associations could not be evaluated further given limited available data as well as disparate exposure measures, distributions, and contrasts being examined. In contrast, the Wikström et al. (2020) study was prioritized for RfD derivation as it was a high confidence study that predominately sampled maternal plasma during the first trimester thereby reducing uncertainty relating to pregnancy hemodynamics. Further confidence in the osRfD derived from the (Wikström et al., 2020) study is provided by the fact that the PODs from the (Wikström et al., 2020) and (Valvi et al., 2017) studies are relatively close (see Table 5-14 above). While not presented in this Toxicological Review, additional birth weight studies were BMD modeled to provide a sensitivity analysis for the comparison of birth weight effects; please see Table C-8 of the Supplemental Appendices. These studies are either medium confidence and/or have later trimester sampling and thus not considered in the dose-response analysis. The PODs from these birth weight studies are relatively close (varying by ~threefold), providing further confidence in using the POD from the (Wikström et al., 2020) study for RfD derivation. In addition to the quantitative implications, the close proximity of the BMDLs from a multitude of birth weight studies increases the confidence in deriving osRfDs despite slight evidence of developmental effects in humans.

### 5.2.3 Subchronic toxicity values for oral exposure (subchronic oral reference dose [RfD]) derivation

In addition to providing an RfD for lifetime exposure in health systems, this document also provides an RfD for less-than-lifetime ("subchronic") exposures. Datasets considered for the subchronic RfD were based on endpoints advanced for RfD derivation in Table 5-10. Given that the developmental and immune effects were observed in humans exposed to PFDA during susceptible lifestages (postnatal growth/development and immune system effects in children at ages 5–7), these endpoints were also considered for the derivation of candidate subchronic values, applying identical uncertainty factors to those used for the lifetime candidate values (see Table 5-15 below).

Similar to the derivation of the lifetime RfD, the developmental effects observed in mice from the Harris and Birnbaum (1989) study were not advanced for the derivation of candidate subchronic values. The developmental PODs from human studies are 6–7 orders of magnitude more sensitive than the POD from the rodent study (see Table 5-10), and were, therefore, prioritized. In addition, endpoints for hepatic, male reproductive toxicity, and female reproductive toxicity observed in the 28-day rodent study (NTP, 2018) were considered for the derivation of subchronic toxicity values. As compared with the large uncertainty in extrapolating the available 28-day studies to lifetime PFDA exposure in the context of the RfD, it was considered reasonable to try to extrapolate the 28-day study data for the purposes of deriving subchronic candidate values.

The use of animal data for hepatic, male reproductive, and female reproductive endpoints required the application of different uncertainty factors than those used for developmental and immune effects in humans and can be found in Table 5-15.

Table 5-15 Uncertainty factors for the development of the candidate subchronic values for PFDA

UF | Value | Justification
UF_A_ | 1; 3 | A UF_A_ of 1 is applied to developmental and immunological effects observed in epidemiological studies.; A UF_A_ of 3 is applied to account for uncertainty in characterizing the pharmacokinetic and pharmacodynamic differences between mice or rats and humans following oral PFDA exposure. Aspects of the cross-species extrapolation of pharmacokinetic processes have been accounted for by using a PK approach that interpolated measured PFDA serum concentrations in rats from the NTP 28-d bioassay, EPA’s custom PK model for mice (incorporating mouse-specific PFDA PK parameters) and a PFDA clearance estimated from human data; however, some residual pharmacokinetic uncertainty remains as does the potential for pharmacodynamic differences. Availability of chemical-specific data justifies the selection of a UF of 3 for PFDA. See discussion below for more details.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability in humans in the absence of quantitative information on potential differences in pharmacokinetics and pharmacodynamics relating to PFDA exposure in humans.
UF_S_ | 1; 10 | A UF_S_ of 1 is applied to developmental delays (i.e., decreased birth body weight) Wikström et al. (2020); and reduced antibody responses in children (Budtz-Jørgensen and Grandjean, 2018a); (Grandjean et al., 2012).The developmental period is recognized as a susceptible lifestage when exposure during a time window of development is more relevant to the induction of developmental effects than subchronic exposure (U.S. EPA, 1991).; A UF_S_ of 10 is applied to liver, male reproductive, and female reproductive effects in adult animals (increased AST levels, decreased epididymis weight and decreased number of days in estrus, respectively) because of the short exposure duration (28 d) and the presumption that effects would worsen with longer exposures. See discussion below for more details.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation when the POD is a BMDL or a NOAEL. All PODs considered for candidate subchronic values were BMDLs.
UF_D_ | 3 | A UF_D_ of 3 is applied to account for deficiencies and uncertainties in the database. Although limited, the evidence base in laboratory animals consists of high/medium confidence short-term studies in rodents and a high confidence developmental study in mice. The database for PFDA also includes several high/medium confidence epidemiological studies most informative for immune and developmental effects. However, uncertainties remain regarding the lack of studies of potential multigenerational effects, and studies of postnatal development, neurotoxicity, and thyroid toxicity during developmental lifestages. In all, the data are too sparse to conclude with certainty that the quantified developmental effects are likely to be the most sensitive; thus, a UF_D_ of 1 was not selected. However, a UF_D_ of 10 was also not selected give the availability of data from well-conducted studies in multiple species, including developmental and short-term rodent studies examining a range of potentially sensitive health outcomes and sensitive evaluations of developmental and immune endpoints in humans.
UF_C_ | See Table 5-16 | Composite Uncertainty Factor = UF_A_ × UF_H_ × UF_S_ × UF_L_ × UF_D_

As described above under “Derivation of candidate lifetime toxicity values for the RfD, " and in (U.S. EPA, 2002), five possible areas of uncertainty and variability were considered in deriving the candidate subchronic values for PFDA. In general, the explanations for these five possible areas of uncertainty and variability and the values assigned to each as a designated UF to be applied to the candidate POD_HED_ values are listed above and in Table 5-15, including the UF_D_, which remained at 3 because of data gaps discussed previously in the derivation of the lifetime RfD. One UF that differs between subchronic and chronic RfDs is that for effects (i.e., decreased fetal body weight, increase AST levels, decreased whole epididymis weight, and decreased estrus time) observed in rodents. A UF_A_ of 3 was applied to account for pharmacokinetic and pharmacodynamic differences between rodents and humans following oral PFDA exposure. As is usual in the application of this uncertainty factor, the pharmacokinetic uncertainty is partly addressed through the application of an adjustment factor, in this case, chemical-specific dosimetric data for estimating human equivalent doses (see “Approach for Pharmacokinetic Extrapolation of PFDA among Rats, Mice, and Humans" in Section 3.1.7 and “Application of Animal-Human Pharmacokinetic Extrapolation of PFDA Toxicological Endpoints and Dosimetric Interpretation of Epidemiological Endpoints" in Section 5.2.1). This application leaves some residual uncertainty around the pharmacokinetics and the uncertainty surrounding differences in pharmacodynamic differences between animals and humans. Typically, a UF_A_ of 3 is applied for this uncertainty when either BW^3/4^ scaling or chemical-specific information is used for dose extrapolation, which is the case for mouse developmental and the rat male and female reproductive endpoints. For the liver endpoint, available mechanistic and supplemental information is considered further in determining the most appropriate value for the UF_A_ to account for the uncertainty.

Evidence from in vitro studies suggest that PFDA interacts with several human receptor pathways relevant to its mechanism of hepatotoxicity, including PPARα. PFDA can bind and activate PPARα in vitro, but reduced or no sensitivity toward the human PPARα versus other mammalian isoforms (i.e., mouse, Baikal seal and polar bear PPARα isoforms) is apparent (Ishibashi et al., 2019; Routti et al., 2019; Wolf et al., 2012; Wolf et al., 2008) and similar findings have been demonstrated for some other perfluorinated compounds. If PPARα were the only operant MOA for noncancer effects in the liver, this observation might support reducing the remaining portion of the UF_A_ to 1, as it could be argued that humans are not as sensitive as wild-type rats are to the hepatic effects of PFDA exposure (note: without evidence to the contrary, as mentioned in the previous paragraph, the toxicodynamic portion of this UF is typically assigned a value of 3 assuming responses manifest in humans could be more sensitive than those observed in animals). Although PPARα appears to be an important mechanism of PFDA-induced liver toxicity in animals and reduced sensitivity in PPAR activation in humans compared with rodents has been suggested, available evidence for PFDA in PPARα null mice, human in vitro assays and in vivo animal models more relevant to humans with respect to PPARα sensitivity (i.e., guinea pigs and Syrian hamsters) suggest that liver effects occur, at least in part, independent of PPARα (see “Summary of Mechanistic Studies" for PFDA in Section 3.2.1). A plausible PPARα-dependent and independent MOA for liver effects is also supported by studies in null and humanized animal models of structurally related long-chain PFAS [C7-C9] (see “Evidence from Related PFAS" in Section 3.2.1), which are mostly lacking for PFDA (a few studies in null mice but no humanized models). Considering the remaining uncertainty in additional MOAs that appear active in PFDA-induced liver effects, and the relative contribution of these MOAs to toxicity in humans compared with rodents, uncertainties surrounding a potential multifaceted MOA for PFDA-induced liver effects, a value of 3 was selected for the UF_A_ for the purposes of deriving candidate subchronic toxicity values for hepatic effects.

EPA states that for “short-term and longer-term reference values, the application of a UF analogous to the subchronic-to-chronic duration UF also needs to be explored, as there may be situations in which data are available and applicable, but they are from studies in which the dosing period is considerably shorter than that for the reference value being derived" (U.S. EPA, 2002). This is the case for hepatic, male reproductive and female reproductive endpoints derived from the 28-day NTP (2018) study. Although there is no chemical-specific information to evaluate the potential for increased sensitivity with exposures longer than 28-days (e.g., a 90-day subchronic study), the following considerations are outlined to inform the application of the UF_s_ for duration extrapolation. (U.S. EPA, 2002)

Regarding female reproductive toxicity, PFDA-induced effects on estrous cyclicity were observed to be of large magnitude in the 28-day study. Specifically, PFDA induced a continuous state of diestrus in 100% of rats treated at the highest dose tested (2.5 mg/kg-day) by day 21 (by day 9 of the sixteen days in which vaginal cytology was assessed) (NTP, 2018). Given these data, it is possible that PFDA-induced effects on estrous cyclicity could become more sensitive or lead to more severe downstream effects like infertility with longer exposure durations. For male reproductive effects, the study duration (28 days) was insufficient to cover the entire period of spermatogenesis in rats (~8 weeks), raising concerns about reduced sensitivity for some of the endpoints evaluated and selected for POD derivation (i.e., sperm evaluations). For liver effects, increases in relative liver weights demonstrated a time dependency across short-term exposures. Relative liver weight increased by 17%-56% at 1.15–10 mg/kg-day in rats exposed for 7–14 days and by 12%-127% at 1–16 mg/kg-day in mice exposed during gestion (GD 10–13 and 6–15). Similar magnitudes of liver weight increases were achieved in rodents after 28-day exposure but at lower PFDA doses (10%-102% at 0.125–2.5 mg/kg-day in rats and 16%-81% at 0.089–0.71 mg/kg-day in mice). The limited data for liver weight suggest potential increase in sensitivity with increasing duration, although there is no information on how liver weight or other sensitive liver endpoints (increased AST and ALP levels) are impacted by longer-term exposures (>28 days). Considering the potential for some health effects (prolonged diestrus, sperm measures, and increased liver weight) to worsen with increasing duration and the large uncertainty associated with the lack of any chemical-specific data on whether the effects observed in the short-term study worsen after subchronic exposure, a UFs of 10 is selected for the purposes of deriving candidate subchronic toxicity values from the 28-day toxicity data.

The uncertainty factors described in Table 5-15 and the text above were applied and the resulting candidate subchronic values are shown in Table 5-16. The candidate values are derived by dividing the POD_HED_ by the composite uncertainty factor as shown below.

Candidate values for P F D A = P O D_H E D_ ÷ U F c 5-2

Table 5-16 Candidate values for deriving the subchronic RfD for PFDA

Endpoint | Study/Confidence | Strain/species/sex | POD_HED_ (mg/kg-d) | UF_A_ | UF_H_ | UF_S_ | UF_L_ | UF_D_ | UF_C_ | Candidate value (mg/kg-d)^a^
Immune effects (developmental)
Decreased serum antitetanus antibody concentrations in children at age 7 yr and PFDA measured at 5 yr | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 6.04 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased serum antidiphtheria antibody concentrations at age 7 yr and PFDA concentrations at age 5 yr | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 5.98 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased serum antitetanus antibody concentrations at age 5 yr and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 1.03 × 10^−7^ | 1 | 10 | 1 | 1 | 3 | 30 | 3 × 10^−9^
Decreased serum antidiphtheria antibody concentrations at age 5 yr and perinatal (pregnancy week 32–2 wk postpartum) PFDA concentrations | Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a); medium confidence | Human, male and female | 3.78 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 1 × 10^−10^
Developmental effects
Decreased birth weight | Wikström et al. (2020); high confidence | Human, male and female | 5.44 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased birth weight | Wikström et al. (2020); high confidence | Human, male | 4.85 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Decreased birth weight | Wikström et al. (2020); high confidence | Human, female | 4.56 × 10^−8^ | 1 | 10 | 1 | 1 | 3 | 30 | 2 × 10^−9^
Liver effects
Increased AST | 28-d study NTP (2018); high confidence | SD rat, male | 4.93 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 5 × 10^−7^
Increased AST | 28-d study NTP (2018); high confidence | SD rat, female | 3.70 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 4 × 10^−6^
Increased ALP | 28-d study NTP (2018); high confidence | SD rat, male | 6.25 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 6 × 10^−7^
Increased ALP | 28-d study NTP (2018); high confidence | SD rat, female | 8.24 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 8 × 10^−7^
Increased relative liver weight | 28-d study NTP (2018); high confidence | SD rat, male | 7.21 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 7 × 10^−7^
Increased relative liver weight | 28-d study NTP (2018); high confidence | SD rat, female | 5.92 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 6 × 10^−7^
Increased relative liver weight | 28-d study Frawley et al. (2018); high confidence | SD rat, female (histo-pathology study cohort) | 1.27 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 1 × 10^−6^
Increased relative liver weight | 28-d study Frawley et al. (2018); high confidence | SD rat, female (MPS study cohort) | 1.04 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 1 × 10^−6^
Increased relative liver weight | 28-d study Frawley et al. (2018); high confidence | SD rat, female (TDAR study cohort) | 6.61 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 7 × 10^−7^
Male reproductive effects
Decreased cauda epididymis sperm count | 28-d study NTP (2018); low confidence | SD rat, male | 5.48 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 5 × 10^−6^
Increased Leydig cell atrophy | 28-d study NTP (2018); high confidence | SD rat, male | 3.14 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 3 × 10^−6^
Decreased serum testosterone | 28-d study NTP (2018); high confidence | SD rat, male | 3.14 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 3 × 10^−6^
Decreased absolute testis weight | 28-d study NTP (2018); high confidence | SD rat, male | 6.25 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 6 × 10^−6^
Decreased absolute cauda epididymis weight | 28-d study NTP (2018); high confidence | SD rat, male | 2.94 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 3 × 10^−6^
Decreased absolute whole epididymis weight | 28-d study NTP (2018); high confidence | SD rat, male | 2.77 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 3 × 10^−6^
Female reproductive effects
Decreased number of days spent in estrus | 28-d study NTP (2018); high confidence | SD rat, female | 6.76 × 10^−4^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 7 × 10^−7^
Increased number of days spent in diestrus | 28-d study NTP (2018); high confidence | SD rat, female | 1.12 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 1 × 10^−6^
Decreased relative uterus weight | 28-d study NTP (2018); high confidence | SD rat, female | 3.70 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 4 × 10^−6^
Decreased absolute uterus weight | 28-d study NTP (2018); high confidence | SD rat, female | 3.70 × 10^−3^ | 3 | 10 | 10 | 1 | 3 | 1, 000 | 4 × 10^−6^

a The candidate values for different salts of PFDA would be calculated by multiplying the candidate value for the free acid of PFDA by the ratio of molecular weights. For example, for the ammonium salt the ratio would be: (M W ammonium salt)/(M W free acid) = (531)/(514) = 1.033 . This same method of conversion can be applied to other salts of PFDA, such as the potassium or sodium salts, using the corresponding molecular weights.

#### Selection of Subchronic Toxicity Value(s)

As described above, candidate subchronic values for several health effects associated with PFDA exposure were derived. The subchronic osRfD values selected were associated with decreased serum antibody concentrations for developmental immune effects, decreased birth weight for developmental effects, increased relative liver weight for liver effects, decreased whole epididymis weight for male reproductive effects, and increased number of days spent in diestrus for female reproductive effects. As discussed earlier, these subchronic osRfDs may be useful for certain decision purposes (i.e., site-specific risk assessments with less-than-lifetime exposures). Confidence in each subchronic osRfD is described in Table 5-17 and includes confidence in the study used to derive the quantitative estimate, the overall health effect, specific evidence base, and quantitative estimate for each subchronic osRfD.

Table 5-17 Confidence in the subchronic organ/system-specific RfDs (subchronic osRfDs) for PFDA

Confidence categories | Designation^a^ | Discussion
Immune (developmental) subchronic osRfD = 2 × 10^−9^ mg/kg-d
Confidence in study used to derive the subchronic osRfD | High | Confidence in Grandjean et al. (2012); Budtz-Jørgensen and Grandjean (2018a) was rated as medium primarily due to relatively limited PFDA exposure contrasts, which can decrease study sensitivity in general (HAWC link). Given that the results in this study were statistically significant, EPA concluded that while there were potential study sensitivity concerns at the evaluation stage, the results clearly showed that those concerns were not borne out, and confidence in this study to derive an osRfD was judged to be high.
Confidence in the evidence base supporting this hazard | Medium | Confidence in the evidence base for immune effects is medium based on consistent findings of reduced antibody responses from two medium confidence birth cohort studies (Grandjean et al., 2012); (Grandjean et al., 2017a); (Grandjean et al., 2017b) and a low confidence study in adults (Kielsen et al., 2016). Short-term studies in animals of high/medium confidence provide supportive evidence of immunosuppression after PFDA exposure (Frawley et al., 2018); (NTP, 2018). Some residual uncertainties regarding unexplained inconsistency and potential confounding by other co-occurring PFAS from epidemiological studies and issues with concomitant overt target organ and systemic toxicity in animal studies lower confidence in the available evidence for this hazard. Other limitations include the lack of epidemiological studies or long-term/chronic studies in animals examining effects on the immune system across different developmental lifestages and immunotoxicity categories, including sensitization and allergic response and autoimmunity and autoimmune disease.
Confidence in the quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium. The POD is based on BMD modeling at the lower end of the range of the observed data and a BMDL_1/2SD_ estimate that is associated with a small degree of uncertainty due to potential confounding by PFOA (see Appendix D.1.1 for more details). The POD for decreased tetanus antibodies at age 7 yr was judged to be medium confidence based on a good model fit and was supported by the nearly identical POD for decreased diphtheria antibodies at age 7 yr. Both PODs support the osRfD. A health-protective estimate for human clearance was applied to estimate the POD_HED_ using PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on Uncertainty in the pharmacokinetic modeling of PFDA above). There is also uncertainty as to the most sensitive window of vulnerability with respect to the exposure/outcome measurement timing (BMDs/BMDLs were estimated from PFDA levels measured at age 5 or perinatally and antitetanus antibody concentrations measured at age 7 or 5); (Grandjean et al., 2017b) reported that estimated PFDA “concentrations at 3 mo and 6 mo showed the strongest inverse associations with antibody concentrations at age 5 yr, particularly for tetanus.” Thus, it is possible that adverse effects during infancy could be more sensitive than between ages 5 and 7 yr.
Overall confidence in subchronic osRfD | Medium | The overall confidence in the osRfD is medium and is driven by medium confidence in the evidence base for immune effects and the quantification of the POD.
Developmental subchronic osRfD = 2 × 10^−9^ mg/kg-d
Confidence in study^a^ used to derive osRfD | Medium | Confidence in the Wikström et al. (2020) study for hazard identification was rated as high (HAWC link) for developmental effects. The study was selected for dose-response analysis due to low overall risk of bias and reliable exposure measurements, which had sufficient exposure contrasts and other characteristics that allowed for adequate study sensitivity to detect associations. The Wikström et al. (2020) study demonstrated associations consistent in magnitude for boys, girls, and the overall population. Overall, mean birth weight was considered the most precise and accurate endpoint and not anticipated to be subject to much error. This study was advanced for dose-response analysis, given minimal presumed impact of pregnancy hemodynamics given the early sampling (96% from trimester 1). Wikström et al. (2020) also adjusted for sample timing in their multivariate models and show no differences in models also restricted to trimester 1 samples only. Some uncertainty remains on the potential for confounding by other PFAS (concern primarily for PFNA), which were not examined in this study. Given the potential quantitative impact of this uncertainty, confidence in the use of this study for dose-response analysis was judged as medium rather than high.
Confidence in evidence base supporting this hazard | Medium-low | Confidence in the evidence base for developmental effects is medium. There was consistent evidence for reduced birth weight among multiple human studies, including high-quality studies. However, unlike the Wikström et al., (2020) study used here and noted above, some uncertainty remains in many studies given the predominance of associations that were detected for studies with later pregnancy sampling. The human database also showed some coherence across different measures of fetal growth restriction. In animals, the lone developmental study reported effects on fetal growth that are coherent with effects observed in humans. Some residual uncertainty regarding potential confounding by other co-occurring PFAS from epidemiological studies lowers confidence in the available evidence for this hazard.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on a BMD hybrid approach within the range of the observed data and dosimetric adjustment was based on PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on Uncertainty in the pharmacokinetic modeling of PFDA above).
Overall confidence in osRfD | Medium-low | The overall confidence in the osRfD is medium and is driven by medium-low confidence in the evidence base for developmental effects (i.e., fetal growth restriction).
Liver subchronic osRfD = 6 × 10^−7^ mg/kg-d
Confidence in study^a^ used to derive osRfD | High | Confidence in the NTP (2018) study was rated high based on good or adequate ratings for most study quality domains (HAWC link) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium | Confidence in the evidence base for liver effects is medium. Coherent liver effects for histopathology, serum biomarkers and organ weights were observed across short-term rodent studies (primarily two high confidence 28-d studies) that are supported by mechanistic studies of biological plausibility and possible human relevance. Uncertainties remain due to the absence of longer-term toxicity studies (28 d) and limited information from available epidemiological studies and in vivo models to characterize the role of PPARα and other signaling pathways in the mechanisms of hepatotoxicity of PFDA in both humans and animals.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on BMD modeling within (at the lower end) the range of the observed data and dosimetric adjustment was based on PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on Uncertainty in the pharmacokinetic modeling of PFDA above).
Overall confidence in the subchronic osRfD | Medium | The overall confidence in the osRfD is medium and is primarily driven by medium confidence in both the evidence base supporting this hazard and the quantification of the POD using BMD modeling of data from a high confidence study.
Male reproductive subchronic osRfD = 3 × 10^−6^ mg/kg-d
Confidence in study^a^ used to derive osRfD | High-medium | Confidence in the NTP (2018) study was rated high-medium (HAWC link) since most of male reproductive measures were rated as high, including the basis for the subchronic osRfD (decreased whole epididymis weight), with the exception of sperm measures, which suffered from insensitivity due to short-term exposure. This is supported by the study evaluation results (good or adequate ratings for most study quality domains) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium-low | Confidence in the evidence base for male reproductive effects is medium to low. Coherent effects across several relevant measures, including sperm parameters, histopathology, serum testosterone levels and organ weights were observed in a high confidence 28-d rat study. The findings are supported by evidence of biological plausibility from limited number of mechanistic studies. In spite of the available evidence, some outstanding uncertainties in the database remain, including the absence of longer-term exposure studies (>28 d), developmental or multigenerational studies that evaluate effects in both adults and developing humans and animals. Given these evidence base uncertainties, it is likely that this osRfD is under-protective of all male reproductive effects.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment was based on PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on Uncertainty in the pharmacokinetic modeling of PFDA above).
Overall confidence in the subchronic osRfD | Medium-low | The overall confidence in the osRfD is medium-low and is primarily driven by the medium-low confidence in the evidence base. The high confidence in the study and medium confidence in the quantification of the POD does not fully mitigate the uncertainties associated with medium-low confidence in the evidence base.
Female reproductive subchronic osRfD = 1 × 10^−6^ mg/kg-d
Confidence in study^a^ used to derive osRfD | High | Confidence in the NTP (2018) study is high (HAWC link) given the study evaluation results (i.e., rating of good in all evaluation categories) and characteristics that make it suitable for deriving toxicity values, including the relevance of the exposure paradigm (route, duration, and exposure levels), use of a relevant species, and the study size and design.
Confidence in evidence base supporting this hazard | Medium-low | Confidence in the evidence base for female reproductive effects is medium-low. There were consistent and coherent effects on uterus weight and the estrous cycle in a single high confidence study. Despite the available evidence, limitations of the evidence base for female reproductive effects include the lack of informative human studies and the lack of a subchronic study in animals as well as lack of studies that examined the effect of PFDA on female fertility and pregnancy outcomes in exposed animals. There are also no developmental or multigenerational studies that evaluated effects in both adults and developing humans and animals. Given these evidence base uncertainties, it is likely that this osRfD is under-protective of all female reproductive effects.
Confidence in quantification of the POD_HED_ | Medium | Confidence in the quantification of the POD and osRfD is medium given the POD was based on BMD modeling within the range of the observed data and dosimetric adjustment was based on PFDA-specific pharmacokinetic information, the latter of which involves some residual uncertainty (see discussion on Uncertainty in the pharmacokinetic modeling of PFDA above).
Overall confidence in the subchronic osRfD | Medium-low | The overall confidence in the osRfD is medium-low and is primarily driven by the medium-low confidence in the evidence base. The high confidence in the study and medium confidence in the quantification of the POD does not fully mitigate the uncertainties associated with medium-low confidence in the evidence base.

a All study evaluation details can be found on HAWC (https://hawcprd.epa.gov/assessment/100500072/).

Table 5-18 Organ/system-specific and overall subchronic RfDs for PFDA

System | Toxicity value | Basis | POD_HED_ (mg/kg-d)^a^ | UF_C_ | osRfD (mg/kg-d) | Confidence
Immune (developmental) | Subchronic osRfD | Decreased serum antibody concentrations for both tetanus and diphtheria in children at age 7 yr and PFDA measured at age 5 yr | 6.04 × 10^−8^ based on BMDL½SD from Grandjean et al., (2012); Budtz-Jørgensen and Grandjean (2018a) | 30 | 2 × 10^−9^ | Medium
Developmental | Subchronic osRfD | Decreased birth weight in males and females | 5.44 × 10^−8^ based on BMDL5%RD from Wikström et al., (2020) | 30 | 2 × 10^−9^ | Medium-low
Liver | Subchonic osRfD | Increased liver weight in SD female rats | 5.92 × 10^−4^ based on BMDL10%RD from NTP (2018) | 1, 000 | 6 × 10^−7^ | Medium
Male reproductive | Subchronic osRfD | Decreased absolute whole epididymis weight in SD rats | 2.77 × 10^−3^ based on BMDL1SD from NTP (2018) | 1, 000 | 3 × 10^−6^ | Medium-low
Female reproductive | Subchronic osRfD | Increased number of days spent in diestrus in SD rats | 1.12 × 10^−3^ based on BMDL5%RD from NTP (2018) | 1, 000 | 1 × 10^−6^ | Medium-low
Immune/developmental | Overall subchronic RfD | Decreased antibody concentrations for both tetanus and diphtheria in children at age 7 yr and PFDA measured at age 5 yr; Decreased birth weight in males and females | 6.04 × 10^−8^ based on BMDL½ SD from Grandjean et al., (2012); Budtz-Jørgensen and Grandjean (2018a); 5.44 × 10^−8^ based on BMDL5%RD from (Wikström et al., 2020) | 30 | 2 × 10^−9^ | Medium

a The details of the BMD modeling approach and results can be found in Appendix C.

#### Selection of Subchronic RfD and Confidence Statement

Organ/system-specific and overall subchronic RfD values for PFDA selected in the previous section are summarized in Table 5-18.

From the identified subchronic osRfDs (see Table 5-18), an overall subchronic RfD of 2 × 10^−9^ mg/kg-day based on decreased serum antibody concentrations and decreased birth weight in humans was selected. As described in Table 5-17, confidence in the RfD is medium, based on medium confidence in the immune osRfD (the developmental osRfD was medium-low confidence), noting that there was medium confidence in the quantification of the PODs for both immune (Budtz-Jørgensen and Grandjean, 2018a); (Grandjean et al., 2012) and developmental ((Wikström et al., 2020)) endpoints using BMD modeling. This RfD is the same for both developmental and immune critical effects given that the PODs for these two osRfDs were nearly identical (i.e., 6.04 × 10^−8^ and 5.44 × 10^−8^, respectively) and that identical UFs were applied.

As described above, the toxicity value of 2 × 10^−9^ mg/kg-day for decreased serum antibody concentrations for both diphtheria and tetanus at age 7 and PFDA measured at age 5 was selected for immune effects Budtz-Jørgensen and Grandjean (2018a); Grandjean et al., (2012); and the toxicity value of 2 × 10^−9^ mg/kg-day based on reduced birth weight from the Wikström et al., (2020) study was selected for developmental effects.

The PODs calculated in Table 5-10 from 28-day studies in rodents were selected for each health effect for the derivation of the candidate subchronic toxicity values based on several considerations, including whether there is an endpoint with less uncertainty and/or greater sensitivity, and whether the endpoint is protective of both sexes and all lifestages.

For liver effects, the toxicity value of 6 × 10^−7^ mg/kg-day (BMDL10RD[HED] of 5.92 × 10^−4^ mg/kg-day) for increased liver weight in female rats in the NTP (2018) study was selected as the liver osRfD because it is a reliable marker of hepatotoxicity and represents a more sensitive reference value than other liver endpoints considered for dose-response modeling (see Table 5-16). For male reproductive effects, endpoints with a high confidence rating (i.e., increased Leydig cell atrophy, decreased serum testosterone, decreased testis weight, and decreased epididymis weight [whole and cauda]) were prioritized over endpoints, which suffered from potential sensitivity issues due to short-term study exposure (i.e., decreased epididymal sperm counts). Because the PODs for the prioritized endpoints were similar (HEDs ranging from 2.77 × 10^−3^ to 6.25 × 10^−3^) and consistent with mechanistic evidence that suggest PFDA targets Leydig cells and causes decreased steroidogenesis and androgen deficiency (see Section 3.2.4), the most sensitive POD based on a BMDL1SD(HED) of 2.77 × 10^−3^ mg/kg-day for decreases in whole epididymis weights was selected for derivation, resulting in a subchronic toxicity value of 3 × 10^−6^ mg/kg-day for male reproductive effects. Lastly, the osRfD of 1 × 10^−6^ mg/kg-day (BMDL5RD[HED] of 1.12 × 10^−3^ mg/kg-day) based on increased number of days spent in diestrus was selected for female reproductive effects given its association with infertility as provided by EPA’s Guidelines for Reproductive Toxicity Risk Assessment. This endpoint is also supported by concomitant decreases in estrus time (BMDL5RD[HED] of 6.76 × 10^−4^ mg/kg-day), for which the association with infertility is less clear.

The subchronic osRfDs for liver, male reproductive, and female reproductive effects derived from short-term animal data were several orders of magnitude higher than the subchronic osRfDs for immune and developmental effects in humans; therefore, they were not considered sufficiently protective for consideration in the selection of the overall subchronic RfD. Also, in the case of male and female reproductive effects, confidence in the respective osRfDs was lower compared with the immune osRfD (medium-low vs. medium) due to deficiencies in the evidence base for these health effects.

### 5.2.4 Inhalation Reference Concentration (RfC) Derivation

No studies examining inhalation effects of short-term, subchronic, chronic or gestational exposure for PFDA in humans or animals have been identified, precluding the derivation of an RfC. Existing PBPK models for PFDA were judged insufficiently reliable for estimating human dosimetry for any route of exposure, including possible route-to-route extrapolation. Additionally, no classical PK models were identified that included inhalation dosimetry to support the derivation of an RfC

## 5.3 CANCER TOXICITY VALUES

Considering the limitations in the evidence base across human, animal, and mechanistic studies of PFDA (see Section 3.3) and in accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005), EPA concluded that the evidence is inadequate to assess carcinogenic potential of PFDA in humans. The lack of adequate carcinogenicity data for PFDA precludes the derivation of quantitative estimates of either oral (oral slope factor [OSF]) or inhalation (inhalation unit risk [IUR]) exposure.

27 The systematic review protocol for PFDA (see Appendix A) defines perfluoroalkyl carboxylic acids with seven or more perfluorinated carbon groups and perfluoralkane sulfonic acids with six or more perfluorinated carbon groups as “long-chain” PFAS. Thus, PFffxA and PFBA are considered short-chain PFAS, whereas PFHxS is considered a long-chain PFAS.

28 IRIS Toxicological Review of Perfluorobutanoic Acid (PFBA, CASRN 375-22-4) and Related Salts {U.S. EPA, 2022, 10692791}.

29 Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3), (U.S. EPA, 2021b).

30 Health Based Guidance for Water: Toxicological Summary for: Perfluorohexane sulfonate (PFHxS), MDH (2019).