# 4 SUMMARY OF HAZARD IDENTIFICATION CONCLUSIONS

## 4.1 SUMMARY OF CONCLUSIONS FOR NONCANCER HEALTH EFFECTS

The available evidence indicates hazards likely exist with respect to liver, immune, developmental, and male and female reproductive effects in humans, given sufficient perfluorodecanoic acid (PFDA) exposure conditions.^18^ Additionally, the available evidence suggests that PFDA exposure might also have the potential to cause cardiometabolic and neurodevelopmental effects in humans given sufficient exposure conditions^19^. These judgments were derived primarily from epidemiological studies and studies in experimental animals, the latter exposed to PFDA during short-term (7–28 days) and developmental (GD 6–15) oral exposures. On the other hand, there is inadequate evidence for urinary, endocrine, and other health effects to determine the potential for health hazards in humans with PFDA exposure. A summary of the justifications for the evidence integration judgments for each of the main hazard sections is provided below.

The hazard identification judgment that the evidence indicates PFDA exposure is likely to cause liver effects in humans, given sufficient exposure condition^20^ is based on animal evidence of concordant effects for increased liver weight, alterations in levels of serum biomarkers of liver injury (ALT, AST, ALP, bile salts/acids, bilirubin and blood proteins), and some evidence of hepatocyte degenerative or necrotic changes that provide support for the adversity of PFDA-induced liver toxicity reported in high and medium confidence studies in rats and mice exposed to PFDA doses ≥0.156 mg/kg-day. Although associations between serum ALT levels and PFDA exposure in epidemiological studies of adults were observed, the epidemiological evidence overall is uncertain due to unexplained inconsistency in the results for other clinical markers and a lack of clear evidence of adversity. Mechanistic studies in rodents and limited evidence from in vitro studies and animal models considered more relevant to humans provide support for the biological plausibility and human relevance of the apical effects observed in animals and suggest a possible PPARα-dependent and independent MOA for PFDA-induced liver toxicity.

The hazard identification judgment that the evidence indicates PFDA exposure is likely to cause immunosuppression in humans, given sufficient exposure conditions^21^, is based on moderate human evidence of immunosuppression primarily from two medium confidence studies in children and one low confidence study in adults at levels of 0.3 ng/mL (median exposure in studies observing an adverse effect). Although some evidence for coherent immunomodulatory responses consistent with immunosuppression (decreases in phagocytic activity of liver microphages, spleen cell counts and immune organ weights and immune organ histopathology) was identified in short-term, high, and medium confidence studies in rats and mice at ≥0.089 mg/kg-day, the animal evidence overall is uncertain. Issues with overt organ and general systemic toxicity pose limitations with respect to the interpretation of the animal evidence. Although possible effects of hypersensitivity-related responses were reported in one epidemiological study and one high-exposure study in mice (21.4 mg/kg-day), outstanding uncertainties remain to draw specific conclusions for this outcome.

The hazard identification judgment that the evidence indicates PFDA exposure is likely to cause developmental toxicity, given sufficient exposure conditions^22^, is based primarily on consistent findings of dose-dependent decreases in fetal weight in mice gestationally exposed to PFDA doses ≥0.5 mg/kg-day, supported by evidence of decreased birth and childhood weight from studies of exposed humans in which PFDA was measured during pregnancy. The conclusion is further supported by coherent epidemiological evidence for biologically related effects (e.g., decreased birth length).

The hazard identification judgment that the evidence indicates PFDA exposure is likely to cause potential adverse effects to the male reproductive system in humans, given sufficient exposure conditions^23^, is based on a coherent pattern of effects on sperm counts, testosterone levels, and male reproductive histopathology and organ weights at doses ≥0.625 mg/kg-day in adult rats exposed for 28 days (high confidence for most endpoints evaluated). Although the MOA for PFDA-induced male reproductive effects is unknown, a few acute i.p. and in vitro rodent studies suggest a possible mechanism via disruption of Leydig cell function and impaired steroidogenesis. Evidence from a medium confidence epidemiological study reported nonstatistically significant decreases in testosterone levels and altered sperm parameters but the findings are inconsistent and imprecise.

The hazard identification judgment that the evidence indicates PFDA exposure is likely to cause female reproductive toxicity in humans given sufficient exposure conditions^24^ is based primarily on the results of a high confidence study in rats showing biologically coherent effects on uterus weight and the estrous cycle after oral exposure to PFDA at ≥1.25 mg/kg-day for 28 days. Although human studies are available for examining associations between PFDA and female reproductive toxicity (e.g., fecundity), the results were mostly null, possibly due to their low sensitivity for observing effects.

The hazard identification judgment that the evidence suggests PFDA exposure has the potential to cause cardiometabolic effects in humans given sufficient exposure conditions^25^ is based primarily on associations between PFDA and serum lipids, adiposity, cardiovascular disease, and atherosclerosis in a few epidemiological studies. However, evidence is largely inconsistent across studies, which adds considerable uncertainty. Evidence in experimental animals from a high confidence rat study was indeterminate.

The hazard identification judgment that the evidence suggests PFDA exposure has the potential to cause neurodevelopmental effects in humans given sufficient exposure conditions^26^ is based on associations between PFDA exposure and outcomes related to attention and behavior, although there is high degree of uncertainty due to inconsistencies and imprecision in the results. No relevant animal studies were available.

Finally, there is inadequate evidence to evaluate the potential for PFDA exposure to cause effects on the endocrine system, urinary system, and other health outcomes in adult humans (i.e., respiratory, digestive, dermal, musculoskeletal, and hematological systems, and nonspecific clinical chemistry). The available data from human and/or animal studies for these health outcomes was largely limited or lacked consistency and coherence. Further, the absence of studies examining the potential for effects of PFDA exposure on the thyroid in developing organisms, or on mammary glands, represent data gaps in light of associations observed for other PFAS, such as PFBS, PFOS, and PFOA (ATSDR, 2021; U.S. EPA, 2018), see Table 4-1 below.

Table 4-1 Hazard conclusions across published EPA PFAS human health assessments

Health outcome | | | EPA PFAS assessments^a, b^
Health outcome | PFDA | PFHxA | PFBA | PFBS | GenX chemicals | PFOA^c^ | PFOS^c^
Thyroid | − | + | + | + | −^d^ | ± | ±
Liver | + | + | + | − | + | + | +
Developmental | + | + | + | + | ± | + | +
Reproductive | + | − | − | − | ± | ± | ±
Immunotoxicity | + | − | − | − | ± | + | +
Renal | − | − | − | + | ± | ± | ±
Hematological | − | + | − | −^d^ | ± | − | −
Ocular | − | −^d^ | − | −^d^ | −^d^ | − | −
Serum Lipids | ± | −^d^ | −^e^ | − | −^d^ | + | +
Hyperglycemia | − | −^d^ | −^e^ | −^d^ | −^d^ | ± | ±
Nervous System | ±^e^ | − | −^e^ | −^d^ | −^d^ | ± | ±
Cardiovascular | ± | −^d^ | −^e^ | − | −^d^ | + | +
Cancer | − | − | − | − | ± | + | +

a Assessments used multiple approaches in summarizing their noncancer hazard conclusions; for comparison purposes, the conclusions are presented as follows: ‘+’ = evidence demonstrates or evidence indicates (e.g., PFDA), or evidence supports (e.g., PFBS); ‘±‘ = suggestive evidence; ‘−‘ = inadequate evidence (e.g., PFDA) or equivocal evidence (e.g., PFBS); and ‘−/−‘ = sufficient evidence to conclude no hazard (no assessment drew this conclusion).

b The assessments all followed the EPA carcinogenicity guidelines (2005); a similar presentation to that used to summarize the noncancer judgments is applied for the cancer hazard conclusions, as follows: ‘+’ = carcinogenic to humans or likely to be carcinogenic to humans; ‘±‘ = suggestive evidence of carcinogenic potential; ‘−‘ = inadequate information to assess carcinogenic potential; and ‘−/−‘ = not likely to be carcinogenic to humans (no assessment drew this conclusion).

c The hazard conclusions were taken from the EPA OW assessments for PFOA (U.S. EPA, 2024b) and PFOS (U.S. EPA, 2024a).

d No data available for this outcome for this PFAS, so ‘– ‘entered by default.

e Data available for PFDA includes neurodevelopmental outcomes in humans.

## 4.2 SUMMARY OF CONCLUSIONS FOR CARCINOGENICITY

Given the limited scope and utility of the available evidence across human, animals, and genotoxicity studies, the evidence is judged to be insufficient to determine whether PFDA exposure (via any exposure route) might affect the development of any specific cancer types. In accordance with EPA cancer guidelines (U.S. EPA, 2005), a weight-of-evidence descriptor of inadequate to assess the carcinogenic potential is assigned for PFDA.

## 4.3 CONCLUSIONS REGARDING SUSCEPTIBLE POPULATIONS AND LIFESTAGES

Understanding of potential areas of susceptibility to the identified human health hazards of PFDA can help to inform expectations of variability in responses across individuals, as well as uncertainties and confidence in candidate toxicity values (see Section 5.2). The available human and animal studies indicate that early life represents a susceptible lifestage for the effects of PFDA exposure. Two medium confidence studies reported immune effects (i.e., decreased antibody response) in children exposed to PFDA during gestation and childhood (Grandjean et al., 2017b) and (Grandjean et al., 2017a; Grandjean et al., 2012). Additionally, developmental effects (i.e., fetal growth restriction, gestational duration, postnatal growth, and spontaneous abortion) were reported in multiple high-quality studies (Buck Louis et al., 2018; Gyllenhammar et al., 2018; Meng et al., 2018; Lind et al., 2017a; Swedish Environmental Protection Agency, 2017; Valvi et al., 2017; Woods et al., 2017; Bach et al., 2016; Kwon et al., 2016; Lenters et al., 2016; Wang et al., 2016; Robledo et al., 2015). The strongest and most consistent evidence was observed for fetal growth restriction. Potentially coherent with these epidemiological observations, effects in developing rodents (decreased fetal body weight, skeletal variations, decreased live fetuses per litter) after maternal exposure also support the potential for early-life susceptibility. Young individuals may also be susceptible to PFDA-induced male reproductive effects. Although no animal studies and only a few human studies are available that examined reproductive effects in early lifestages (i.e., pubertal development and anogenital distance), effects on sperm motility and testosterone were consistently reported in exposed human and rodent adults (NTP, 2018; Zhou et al., 2016; Joensen et al., 2013). Given the potential for PFDA to impair androgen function, boys exposed during critical developmental lifestages may be susceptible as exposure during gestation and early postnatal lifestages could result in agenesis of the male reproductive system and/or infertility.

Although inconclusive, some effects on thyroid hormone homeostasis were observed in adult rats (NTP, 2018). Although no studies are available that assessed the effect of PFDA on thyroid hormones in developing organisms, young individuals exposed during gestation, early childhood, and puberty may be a susceptible population given that triiodothyronine (T3) and thyroxine (T4) levels play critical roles in bone growth and brain development (O'Shaughnessy et al., 2019) at these lifestages (i.e., both pregnancy and early life). PFDA was also observed to disrupt estrous cyclicity in female rats with potential implications for impaired fertility (NTP, 2018). Therefore, although the current evidence does not explicitly address the potential for a linkage between these observations and impaired fertility in women, women of reproductive age may also be susceptible to the effects of PFDA exposure.

18 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

19 The “sufficient exposure conditions" are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

20 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

21 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

22 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

23 The “sufficient exposure conditions” are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

24 The “sufficient exposure conditions" are more fully evaluated and defined for the identified health effects through dose-response analysis in Section 5.

25 Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define what might be the “sufficient exposure conditions" for developing these outcomes (i.e., these health effects are not advanced for dose-response analysis in Section 5).

26 Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define what might be the “sufficient exposure conditions” for developing these outcomes (i.e., these health effects are not advanced for dose-response analysis in Section 5).