# 2 LITERATURE SEARCH RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

The database searches yielded 1, 330 unique records, including records identified from additional sources, such as posted National Toxicology Program (NTP) study tables, review of reference lists from other authoritative sources (ATSDR, 2018b), searches of published per- and polyfluoroalkyl substances systematic evidence maps (Pelch et al., 2022) and studies submitted to EPA during public comment and external peer review (see Figure 2-1). Of the 1, 330 studies identified, 426 were excluded during title-and-abstract screening that did not meet PECO and did not contain potentially relevant supplemental information, and 627 were reviewed at the full-text level. Of the 627 studies screened at the full-text level, 372 were considered to meet the populations, exposures, comparators, and outcomes (PECO) eligibility criteria (see Table 1-4). The PECO criteria identify the evidence that addresses the specific aims of the assessment and focuses the literature screening, including study inclusion/exclusion. In addition to those studies meeting the PECO criteria, studies containing supplemental material potentially relevant to the specific aims of the assessment were tagged during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues and other major scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material" included the following:

- In vivo mechanistic or mode-of-action studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and non-PECO populations (e.g., nonmammalian models);
- In vitro and in silico models;
- Absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic (PK) studies (excluding models);
- Exposure assessment or characterization (no health outcome) studies; and
- Human case reports or case-series studies

The studies meeting PECO at the full-text level included 342 epidemiologic studies, 14 animal studies, 2 physiologically based pharmacokinetic (PBPK) model and 8 in vitro/in vivo genotoxicity studies, and 9 accessory records or supplementary materials included in epidemiological and animal studies. Of the 1, 330 studies screened, 498 were identified as supplemental material during title-and-abstract or full-text screening and tagged by topic area (e.g., in vivo mechanistic or MOA, ADME). High-throughput screening data on perfluorodecanoic acid (PFDA) are currently available from the EPA’s Chemicals Dashboard U.S. EPA (2022a), (data were retrieved in November 2022) and relevant information is presented and analyzed in Appendix E. The last literature search update used for the Toxicological Review was April 2023.

Figure 2-1 Literature search for perfluorodecanoic acid and related salts.

^a^The numbers for the different litarature databses and other sources do not account for duplicates. See the HERO page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614) for this assessment for more details.

Figure 2-1. Literature search flow chart.

## 2.2 SUMMARY OF STUDIES MEETING PECO CRITERIA

Human and animal studies have evaluated potential effects to the liver, immune system, developing fetus, male and female reproductive systems, endocrine, cardiometabolic, neurodevelopmental, urinary, general toxicity, and other organ systems (e.g., hematology) following exposure to PFDA. The evidence base for these outcomes is synthesized in Sections 3.2.1–3.2.11. A limited number of available studies in humans and animals informative of potential carcinogenic effects with PFDA exposure are summarized in Section 3.3. The two identified PBPK models are discussed in Section 3.1.

Three hundred and forty-two epidemiological studies were identified that reported on the potential association between PFDA and noncancer and cancer human health effects (list of studies filterable by health effect available at: https://hawcprd.epa.gov/summary/visual/assessment/100500072/Epi-studies-of-PFDA-health-effects/ (https://hawcprd.epa.gov/summary/visual/assessment/100500072/Epi-studies-of-PFDA-health)). The database of animal toxicity studies for PFDA consists of oral exposure studies (see Table 2-1), including five dietary exposure studies in rats exposed for 7–14 days (Yamamoto and Kawashima, 1997; Kawashima et al., 1995; Permadi et al., 1993; Takagi et al., 1992, 1991); two drinking water studies in mice exposed for 12–49 days (Li et al., 2022; Wang et al., 2020), two 28-day gavage studies in rats and/or mice (Frawley et al., 2018; NTP, 2018), one 14-day oral study (presumed to be gavage) in mice (Lee and Kim, 2018), and one gestational exposure study in mice via gavage with two exposure windows (GD 10–13 and 6–15) (Harris and Birnbaum, 1989). In addition, three single exposure studies in animals via the oral route were identified with limited utility for the evaluation of repeat-dose toxicity and the derivation of oral reference dose (RfD) values (Kawabata et al., 2017; Brewster and Birnbaum, 1989; Harris et al., 1989).

Table 2-1 Animal toxicity studies examining health effects after PFDA administration

Author (year) reference | Species, strain (sex) | Exposure route and duration | Dose range^a^
NTP (2018) | Rat, Harlan Sprague-Dawley (male and female) | Oral gavage; daily over 28 d | 0, 0.156, 0.312, 0.625, 1.25 and 2.5 mg/kg-d
Frawley et al. (2018) | Rat, Harlan Sprague-Dawley (female) | Oral gavage; daily over 28 d | 0, 0.125, 0.25 and 0.5 mg/kg-d
Frawley et al. (2018) | Mouse, B6C3F1/N (female) | Oral gavage; weekly over 28 d | 0.04464, 0.0893, 0.179, 0.36 and 0.71 mg/kg-d (reported as 0, 0.3125, 0.625, 1.25, 2.5 and 5 mg/kg-wk)
Takagi et al. (1991) | Rat, F344 (male) | Diet; daily over 14 d | 0, 10 mg/kg-d (reported as 0% and 0.01%)
Lee and Kim (2018) | Mouse, ICR (male) | Uncharacterized (presumed to be oral gavage); days 9, 11, and 13 over 14 d | 0 and 21.4 mg/kg-d (reported as 0 and 100 mg/kg)
Li et al. (2022) | Mouse, C57BL/6J (female) | Drinking water; daily for 14 d | 0 and 25 mg/kg-d
Wang et al. (2020) | Mice, CD-1 (male) | Drinking water; daily over 12–49 d | 0, 13 mg/kg-d (reported as 0 and 0.1 mM)
Permadi et al. (1993) | Mouse, C57BL/6 (male) | Diet; daily over 10 d | 0, 37.8 mg/kg-d (reported as 0% and 0.02%)
Kawashima et al. (1995) | Rat, Wistar (male) | Diet; daily over 7 d | 0, 1.15, 2.3, 4.6, and 9.22 mg/kg-d (reported as 0, 00125%, 0.0025%, 0.005%, and 0.01%)
Yamamoto and Kawashima (1997) | Rat, Wistar (male) | Diet; daily over 7 d | 0 and 4.6 mg/kg-d (reported as 0% and 0.005%)
Takagi et al. (1992) | Rat, Fisher F344 (male) | Diet; daily over 7 d | 0 and 10 mg/kg-d (0% and 0.01%)
Harris and Birnbaum (1989) | Mouse, C57BL/6N (female) | Oral gavage; GD 10–13 | 0, 0.25, 0.5, 1, 2, 4, 8, 16, and 32 mg/kg-d
Harris and Birnbaum (1989) | Mouse, C57BL/6N (female) | Oral gavage; GD 6–15 | 0, 0.03, 0.1, 0.3, 1, 3, 6.4, and 12.8 mg/kg-d

GD = gestational day.

a Doses are presented as adjusted daily doses (ADD). Additional details on the ADD conversions can be found in the HAWC project page for PFDA.

Graphical representations of outcome-specific study evaluations are presented and discussed within the hazard sections outlined above. Detailed rationales for each domain and overall confidence rating are available in Health Assessment Workspace Collaborative (HAWC (https://hawcprd.epa.gov/assessment/100500072/)).