# 1 OVERVIEW OF BACKGROUND INFORMATION AND ASSESSMENT METHODS

## 1.1 BACKGROUND INFORMATION ON PERFLUORODECANOIC ACID (PFDA)

Section 1.1 provides a brief overview of aspects of the physicochemical properties, human exposure, and environmental fate characteristics of perfluorodecanoic acid (PFDA; CASRN 335-76-2), and its related salts that might provide useful context for this Toxicological Review. This overview is not intended to provide a comprehensive description of the available information on these topics. The reader is encouraged to refer to source materials cited below, more recent publications on these topics, and the assessment systematic review protocol (see Appendix A).

### 1.1.1 Physical and Chemical Properties

PFDA and its related salts are members of the group of per- and polyfluoroalkyl substances (PFAS). Buck et al. (2011) define PFAS as fluorinated substances that “contain 1 or more C atoms on which all the H substituents (present in the nonfluorinated analogues from which they are notionally derived) have been replaced by F atoms, in such a manner that they contain the perfluoroalkyl moiety C_n_F_2n+1−_).” More specifically, PFDA is classified as a perfluoroalkyl carboxylic acid (PFCA) (OECD, 2018). PFCAs containing seven or more perfluorinated carbon groups are considered long-chain PFAS (ATSDR, 2021). Thus, PFDA is a long-chain PFAS. The chemical structures of PFDA and some of its related salts are presented in Figure 1-1.^7^ The physicochemical properties of PFDA and these related salts are provided in Table 1-1.

Figure 1-1 Chemical structure of PFDA and related salts.

Figure 1-1, chemical structures.

Table 1-1 Physicochemical properties of PFDA and related salts

Property (unit) | Value
Property (unit) | PFDA 335-76-2 | PFDA NH_4_^+^ salt 3108-42-7 | PFDA Na^+^ salt 3830-45-3
Molecular weight (g/mol) | 514^a^ | 531^a^ | 536^a^
Melting point (°C) | 82.0^a^ | 83.0^a,*^ | 84.0^a,*^
Boiling point (°C) | 198^a^ | 212^a,*^ | 212^a,*^
Density (g/cm^3^) | 1.79^a,*^ | 1.76^a,*^ | 1.76^a,*^
Vapor pressure (mm Hg) | 1.53e–3^a^ | 2.39e–02^a,*^ | 2.39e–02^a,*^
Henry’s law constant (atm-m^3^/mole) | 1.51e−10^a,*^ | 1.51e−10^a,*^ | 1.51e−10^a,*^
Water solubility (mol/L) | 5.25e–3^a^ | 1.21e−3^a,*^ | 1.21e−3^a,*^
PKa | 0.4^a,*^ | 0.4^a,*^ | 0.4^a,*^
LogP | 4.15^a^ | 7.11^a,*^ | 6.84^a,*^
Soil adsorption coefficient (L/kg) | 398^a,*^ | 398^a,*^ | 398^a,*^
Bioconcentration factor (BCF) (L/kg) | 49.3^a^ | 29.5^a,*^ | 29.5^a,*^

* Predicted value.

a U.S. EPA (2019b) U.S. EPA CompTox Chemicals Dashboard: https://comptox.epa.gov/dashboard/dsstoxdb/results?search=PFDA. When available, average experimental values are provided in the table but average predicted values that may be less reliable are included in the absence of experimental data. All values from the U.S. EPA CompTox Chemicals Dashboard were accessed on January 17, 2024.

### 1.1.2 Sources, Production, and Use

PFAS are not naturally occurring in the environment (ATSDR, 2021). They are synthetic compounds that have been used widely over the past several decades in consumer products and industrial applications because of their resistance to heat, oil, stains, grease, and water. This class of chemicals has been used in consumer products including stain-resistant fabrics for clothing, carpets, and furniture; nonstick cookware; and personal care products (e.g., dental floss, cosmetics, and sunscreen) (ATSDR, 2024, 2021, 2018a).

PFDA has been used in stain and grease-proof coatings on food packaging, furniture, upholstery, and carpet (Harbison et al., 2015). Kotthoff et al. (2015) analyzed a variety of consumer products for PFAS. PFDA was detected in nano- and impregnation-sprays, outdoor textiles, carpet, gloves, paper-based food contact materials, ski wax, and leather.

EPA has been working with companies in the fluorochemical industry since the early 2000s to phase out the production and use of long-chain PFAS such as PFDA (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-PFAS). However, the production and use of PFAS has resulted in their release to the environment through various waste streams. Also, because products containing PFAS are still in use, they may continue to be a source of environmental contamination due to disposal or breakdown in the environment (Kim and Kannan, 2007).

No Chemical Reporting Data (CDR) on production volume are available in EPA’s ChemView (U.S. EPA, 2019a) for PFDA or its salts. As part of the National Defense Authorization Act for Fiscal Year 2020 (see Section 7321), 172 per- and polyfluoroalkyl substances, including PFDA, were added to the EPA’s Toxic Release Inventory (TRI) list (https://www.epa.gov/toxics-release-inventory-tri-program/tri-listed-chemicals). The reporting requirements apply to a de minimus limit of 1% and a manufacture, process, or otherwise use threshold of 100 lbs. The 2022 TRI Report documented 3, 400 pounds of PFDA disposed on-site or otherwise released for all industries (https://enviro.epa.gov/triexplorer/release_chem?p_view=USCH&trilib=TRIQ1&sort=_VIEW_&sort_fmt=1&state=All+states&county=All+counties&chemical=0000335762&industry=ALL&year=2022&tab_rpt=1&fld=RELLBY&fld=TSFDSP).

Wang et al. (2014b) estimated global emissions of PFDA from direct and indirect (i.e., formation from degradation of precursors) sources between 1951 and 2030 at 8 metric tons based on a lower estimate and 222 metric tons based on a higher estimate. The lower estimate assumes that producers cease production and use of long-chain PFCAs and their precursors in line with global transition trends. The higher estimate assumes that the emission scenario in 2015 remains constant until 2030.

### 1.1.3 Environmental Fate and Transport

Long-chain PFAS, including PFDA, are considered extremely stable and persistent in the environment (ATSDR, 2024, 2018a; Harbison et al., 2015), and can be found worldwide in the environment, wildlife, and humans (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-management-and-polyfluoroalkyl-substances-PFAS). Long-chain PFAS, including PFDA, have been found at private and federal facilities and have been associated with various facilities and have been associated with various sources, including aqueous film-forming foam (AFFF) for fire suppression and PFAS manufacturers and industries that use PFAS (e.g., textiles) (ATSDR, 2021).

Although specific data on PFDA are lacking, PFAS that are released to air have been found to exist in the vapor phase in the atmosphere and resist photolysis, but particle-bound concentrations have also been measured (Kim and Kannan, 2007). Wet and dry deposition are potential removal processes for particle-bound PFAS in air (ATSDR, 2024, 2018a).

In soil, the mobility of PFAS will vary depending on their soil adsorption coefficients (see Table 1-1), with PFDA being moderately mobile. Uptake of soil PFAS to plants has been shown to occur for similar, long-chain PFAS such as PFOA (ATSDR, 2024, 2018a). Yoo et al. (2011) estimated a grass-soil accumulation factor (grass concentration divided by soil concentration) of 0.10 for PFDA that was based on samples collected from a site with bio-solids-amended soil.

The potential for PFAS to bioaccumulate in aquatic organisms is dependent on their bioconcentration factors (see Table 1-1), with the potential being high for PFDA to bioaccumulate compared with most of the other PFAS for which these data are available.

### 1.1.4 Potential for Human Exposure, Including Populations and Lifestages with Potentially Greater Exposure

The general population may be exposed to PFAS via inhalation of indoor or outdoor air, ingestion of drinking water and food, and dermal contact with PFAS-containing products (ATSDR, 2024, 2018a; NLM, 2017, 2013). Exposure may also occur via hand-to-mouth transfer of materials containing these compounds (ATSDR, 2024, 2018a). However, the oral route of exposure has been considered the most important route of exposure among the general population. This conclusion is based on several studies that have investigated the various routes of PFAS exposure (Sunderland et al., 2019). Other authoritative sources on exposure assessment (e.g., ATSDR) continue to conduct human biomonitoring studies on PFAS, including PFDA, and those sources should be consulted for the most up-to-date information on PFDA exposure in humans.

Gebbink et al. (2015) modeled exposure to PFDA among the adult general population. Intermediate exposure (i.e., based on median inputs for all exposure parameters) from direct and indirect (i.e., precursor) sources was estimated at 67 pg/kg-day. Of the pathways evaluated (i.e., ingestion of dust, food, water; inhalation of air), direct intake of PFDA in the diet accounted for the largest portion (51.3%) of exposure for the intermediate scenario. From a systematic evidence map published in 2023 (Holder et al., 2023), the most common pathways for PFDA exposure were food, dust, and drinking water, in accordance with the number of studies that detected the chemical in 50% or more of samples.

The presence of PFAS in human blood provides evidence of exposure among the general population. PFAS have been monitored in the human population as part of the National Health and Nutrition Examination Survey (NHANES). PFDA was measured in serum samples collected in 2013–2014 from more than 2, 000 survey participants (CDC, 2022a, b). The results of these analyses are presented in Table 1-2. Olsen et al. (2017) analyzed human plasma samples from 616 American Red Cross (AMC) donors for PFAS in 2015. The results were compared with results of similar analyses conducted in 2000–2001, 2006, and 2010. Geometric mean concentrations of PFDA declined 50% from 2000–2001 to 2015. Examination of the trend over time from the NHANES dataset also shows a decrease in PFDA levels over time, with a median (25th and 75th percentile) serum concentration that fell from 0.3 (0.2, 0.5) ng/mL in 2005–2006 to 0.2 (0.1, 0.3) ng/mL in 2017–2018. PFDA has also been detected in cord blood and human milk (ATSDR, 2024, 2018a). For example, Lankova et al. (2013) detected PFDA in 10% of human milk samples collected from 50 Czech women at concentrations ranging from <6 to 12 pg/mL, indicating that breastmilk is a potential route of exposure for infants. Exposure can also occur through hand-to-mouth transfer of materials containing these compounds (ATSDR, 2021) or in infants through ingestion of formula reconstituted with contaminated drinking water.

Populations that may experience exposures greater than those of the general population may include individuals in occupations that require frequent contact with PFAS-containing products, such as firefighters or individuals who install and treat carpets (ATSDR, 2024, 2018a). Also, because PFDA can be found in ski wax, individuals who engage in professional ski waxing may be more highly exposed because PFAS in dust may become airborne and inhaled during this process (Harbison et al., 2015). Nilsson et al. (2010) observed a significant correlation between the number of years individuals had worked as ski wax technicians and their blood levels of PFDA.

Populations living near fluorochemical facilities where environmental contamination has occurred may also be more highly exposed (ATSDR, 2024, 2018a). Yamada et al. (2014) estimated exposure to PFDA and other PFAS among high seafood consumers and high freshwater fish consumers in France. Depending on how nondetects were handled (set to zero or the limit of detection), mean estimates for PFDA were 0.16 to 0.73 ng/kg-day for high seafood consumers and 0.42 to 0.96 ng/kg-day for high freshwater fish consumers, compared with the adult general population (0.00 to 0.34 ng/kg-day). Thus, populations with a large portion of their diet from fish, including some tribal groups, may experience disproportionally greater PFDA exposure.

Table 1-2 Serum PFDA concentrations based on NHANES 2013–2014 data (μg/L)

Population group^a^ | Value
Total population (N = 2,168)
Geometric mean | 0.185
50th percentile | 0.200
95th percentile | 0.700
3 to 5 yr (N = 181)
Geometric mean | –^b^
50th percentile | 0.100
95th percentile | 0.370
6 to 11 yr (N = 458)
Geometric mean | –^a^
50th percentile | <LOD^c^
95th percentile | 0.350
12 to 19 yr (N = 402)
Geometric mean | 0.136
50th percentile | 0.100
95th percentile | 0.400
20 yr and older (N = 1, 766)
Geometric mean | 0.193
50th percentile | 0.200
95th percentile | 0.800

LOD = limit of detection.

a This table provides only general context on serum PFDA levels from a single study and within a narrow period (environmental PFDA levels are changing over time). Note that PFDA is expected to bioaccumulate over a lifetime (see Sections 1.1.3 and 3.1). Up-to-date information from authoritative bodies should be used in any decisional context.

b Not calculated because the proportion of results below the limit of detection was too high to provide a valid result.

c Limit of detection was 0.1.

Source: CDC (2022b). Fourth National Report on Human Exposure to Environmental Chemicals.

#### Air and Dust

PFDA is not currently listed as a hazardous air pollutant under the Clean Air Act and has not been evaluated under the National Air Toxics Assessment (https://www.epa.gov/national-air-toxics-assessment) or the Air Toxics Screening Assessment (https://www.epa.gov/AirToxScreen). However, PFDA was measured at concentrations ranging from 0.13 to 1.56 pg/m^3^ in the vapor phase and from 0.13 to 0.49 pg/m^3^ in the particle phase of air samples collected from an urban area of Albany, New York, in 2006 (Kim and Kannan, 2007).

PFAS, including PFDA, have also been measured in indoor air and dust and may be associated with the indoor use of consumer products such as PFAS-treated carpets or other textiles (ATSDR, 2024, 2018a). For example, Strynar and Lindstrom (2008) analyzed dust samples from 110 homes and 10 daycare centers in North Carolina and Ohio in 2000–2001 and detected PFDA in 30.4% of the samples. Similar analyses were conducted by Karásková et al. (2016) who collected 56 dust samples from 41 homes in the Czech Republic, Canada, and the United States in 2013. PFDA was detected in more than 80% of the samples with mean concentrations of 5.2, 8.5, and 6.9 μg/g for the Czech Republic, Canada, and the United States, respectively. Knobeloch et al. (2012) collected vacuum cleaner dust from 39 homes in Wisconsin in 2008 and detected PFDA in 72% of the samples at a median concentration of 5.7 ng/g. Fraser et al. (2013) analyzed dust samples collected from offices (n = 31), homes (n = 30), and vehicles (n = 13) in Boston, Massachusetts, in 2009. PFDA was detected in 97% of the office samples at concentrations ranging from 5.3 to 492 ng/g, 43% of the home samples at concentrations ranging from 7.0 to 26.8 ng/g, and 69% of the vehicle samples at concentrations ranging from 5.4 to 70.1 ng/g. Indoor air samples (n = 4) from a town in Norway collected between 2005 and 2006 had a mean concentration of 3.4 pg/m^3^ for PFDA (Barber et al., 2007).

#### Water

EPA conducted monitoring between 2013 and 2015 for several PFAS (but not PFDA) in drinking water as part of the third Unregulated Contaminant Monitoring Rule (UCMR3). The fifth Unregulated Contaminant Monitoring Rule (UCMR5) requires public water systems to monitor for PFDA and 28 other PFAS (as well as lithium) in drinking water, with sampling collection occurring between 2023 and 2025 (U.S. EPA, 2019c, 2016c). As of April 11, 2024, PFDA has occurred at or above the UCMR 5 minimum reporting level (MRL) (0.003 μg/L) in 13 out of approximately 24, 000 samples at 5 out of approximately 4, 650 PWSs (UCMR 5 Data Summary (epa.gov) (https://www.epa.gov/dwucmr/data-summary-fifth-unregulated-contaminant-monitoring-rule). The UCMR 5 dataset is not complete and will be updated on a quarterly basis until completion of data reporting in 2026. Data are added and possibly removed or updated over the course of this reporting cycle following further review by analytical laboratories, PWSs, states, and EPA. Kim and Kannan (2007) analyzed lake water, rainwater, snow, and surface water from Albany, New York, and reported concentrations of PFDA ranging from undetected to 8.39 ng/L. Konwick et al. (2008) observed elevated PFDA concentrations (30–113 ng/L) in a river in Georgia near the site of a wastewater land application system associated with carpet manufacturing. Washington et al. (2010) analyzed soil samples from agricultural fields in Decatur, Alabama, where wastewater treatment sludges had been applied. PFDA was the PFAS with the highest concentration with a maximum of 990 ng/g.

#### Aqueous Film-Forming Foam Training Sites

PFDA was detected at an Australian training ground where AFFFs had been used (Baduel et al., 2015), and Bräunig et al. (2017) suggested that PFAS were distributed via groundwater to biotic and abiotic matrices in an Australian town impacted by PFAS from a nearby fire-fighting training site. Mean concentrations of PFDA were 0.12 μg/L in water, 0.4 μg/kg dry weight in soil, <0.2 μg/kg wet weight in grass, 0.24 μg/g in egg yolk, 0.21–9.7 μg/L in cow, sheep, and horse serum, and 0.4 μg/L in human serum.

#### Military Sites

PFDA was detected at 10 U.S. military sites in 67.0% of the surface soil samples and in 48.5% of the sediment samples (ATSDR, 2024, 2018a; Anderson et al., 2016). Table 1-3 provides the concentrations of PFDA in soil, sediment, surface water, and groundwater at these military sites.

Table 1-3 PFDA levels at 10 military installations

Media | Value
Surface soil
Frequency of detection (%) | 67.03
Median (μg/kg) | 0.980
Maximum (μg/kg) | 15.0
Subsurface soil
Frequency of detection (%) | 12.50
Median (μg/kg) | 1.40
Maximum (μg/kg) | 9.40
Sediment
Frequency of detection (%) | 48.48
Median (μg/kg) | 1.90
Maximum (μg/kg) | 59.0
Surface water
Frequency of detection (%) | 52.00
Median (μg/kg) | 0.067
Maximum (μg/kg) | 3.20
Groundwater
Frequency of detection (%) | 34.78
Median (μg/kg) | 0.023
Maximum (μg/kg) | 1.80

Source: Anderson et al. (2016); ATSDR (2024, 2018a).

#### Other Exposures

Schecter et al. (2012) collected 31 food samples from five grocery stores in Texas in 2009 and analyzed them for persistent organic pollutants, including PFDA, which was not detected (limit of detection = 0.2 ng/mL) in any of the foods. Chen et al. (2018b) analyzed PFAS, including PFDA, in foods in Taiwan. PFDA was detected in a wide range of foods at geometric mean concentrations ranging from 0.94 ng/mL in milk to 22.2 ng/g in eggs. Heo et al. (2014) analyzed a variety of foods and beverages in Korea for PFAS. PFDA was detected in 1.3% of the fruit and vegetable samples at a mean concentration of 0.0002 ng/g; 12.8% of the meat samples at a mean concentration of 0.132 ng/g; 13.5% of the dairy samples at a concentration of 0.041 ng/g; 19.0% of the beverage samples at a mean concentration of 0.019 ng/L; and 45.5% of the fish and shellfish samples at a mean concentration of 0.056 ng/g. Heo et al. (2014) also detected PFDA in tap water and bottled water in Korea at mean concentrations of 1.19 and 0.014 ng/L, respectively. Pérez et al. (2014) analyzed PFAS in 283 food items (38 from Brazil, 35 from Saudi Arabia, 36 from Serbia, and 174 from Spain). PFDA was detected in 4.5%, 3.4%, and 2.1% of the samples from Brazil, Serbia, and Spain, respectively. The mean concentrations of PFDA in foods from these countries were 170, 267, and 772 pg/g, respectively. Stahl et al. (2014) characterized PFAS in freshwater fish from 164 U.S. urban river sites and 157 near-shore Great Lakes sites. PFDA was detected in fish from 20% of the urban river samples (median = <method detection limit; maximum = 28.5 ng/g) and from 92% of the Great Lakes samples (median = 0.68 ng/g; maximum = 13.0 ng/g).

## 1.2 SUMMARY OF ASSESSMENT METHODS

This section summarizes the methods used for developing this Toxicological Review. A more detailed description of the methods for each step of the assessment development process is provided in the systematic review protocol (see Appendix A). The protocol includes additional problem formulation details, including the specific aims and key science issues identified for this Toxicological Review.

### 1.2.1 Literature Search and Screening

The detailed search approach, including the query strings and populations, exposures, comparators, and outcomes (PECO) criteria (see Table 1-4), is provided in Appendix B. The results of the current literature search and screening efforts are documented in Section 2.1. Briefly, a literature search was first conducted in 2017 and regular yearly updates are performed. The most recent literature search update that was fully incorporated into the assessment is from April 2022. The literature through March 2023 was screened while the document was undergoing public comment. The results of this literature update and any additional unscreened studies identified during public comment and external peer review were screened against the PECO criteria and presented in Tables I-1, I-2, and I-3 of Appendix I in the assessment. The tables provide the identified studies that met PECO criteria or certain supplemental evidence categories (i.e., in vivo mechanistic or MOA studies, including non-PECO routes of exposure and populations; in vitro and in silico models; and absorption, distribution, metabolism, and excretion [ADME] and pharmacokinetic [PK] studies) and EPA's judgment and supporting rationale on whether the studies have a material impact on the assessment conclusions (i.e., identified hazards or toxicity values) presented in the public comment draft. New studies judged influential in informing assessment conclusions and data gaps were incorporated into the relevant section of the assessment prior to finalization.

The literature search queried the following databases (no date or language restrictions were applied):

- PubMed (National Library of Medicine (https://www.ncbi.nlm.nih.gov/pubmed/))
- Web of Science (Thomson Reuters (https://apps.webofknowledge.com/))
- Toxline (National Library of Medicine (https://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?TOXLINE))
- TSCATS (Toxic Substances Control Act Test Submissions (https://cfpub.epa.gov/si/si_public_record_Report.cfm?dirEntryId=2855))

In addition, relevant literature not found through database searching was identified by:

- Review of studies cited in any PECO-relevant studies and published journal reviews; finalized or draft U.S. state, U.S. federal, and international assessments (e.g., the draft Agency for Toxic Substances and Disease Registry [ATSDR] assessment released publicly in 2018). In addition, studies included in ongoing IRIS PFAS assessments (PFHxS and PFNA) were also scanned for any studies that met PFDA PECO criteria.
- Searches of published PFAS systematic evidence maps (SEMs) (Carlson et al., 2022; Pelch et al., 2022) starting in 2021.
- Review of studies submitted to federal regulatory agencies and brought to the attention of EPA; for example, studies submitted to EPA by the manufacturers in support of requirements under the Toxic Substances Control Act (TSCA).
- Identification of studies during screening for other PFAS. For example, epidemiology studies relevant to PFDA were sometimes identified by searches focused on one of the other four PFAS currently being assessed by the IRIS Program.
- Other gray literature (e.g., primary studies not indexed in typical databases, such as technical reports from government agencies or scientific research groups; unpublished laboratory studies conducted by industry; or working reports/white papers from research groups or committees) brought to the attention of EPA.

All literature is tracked in the U.S. EPA Health and Environmental Research Online (HERO) database (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614). The PECO criteria (see Table 1-4) identify the evidence that addresses the specific aims of the assessment and guide the literature screening process.

Table 1-4 Populations, exposures, comparators, and outcomes (PECO) criteria

PECO element | Evidence
Populations | Human: Any population and lifestage (occupational or general population, including children and other sensitive populations). The following study designs will be included: controlled exposure, cohort, case control, and cross-sectional. (Note: Case reports and case series will be tracked as potential supplemental material.); Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).; Other: In vitro, in silico, or nonmammalian models of genotoxicity. (Note: Other in vitro, in silico, or nonmammalian models will be tracked as potential supplemental material.)
Exposures | Human: Studies providing quantitative estimates of PFDA exposure based on administered dose or concentration, biomonitoring data (e.g., urine, blood, or other specimens), environmental or occupational setting measures (e.g., water levels or air concentrations, residential location and/or duration, job title, or work title). (Note: Studies that provide qualitative, but not quantitative, estimates of exposure will be tracked as supplemental material.); Animal: Oral or inhalation studies including quantified exposure to PFDA based on administered dose, dietary level, or concentration. (Note: Nonoral and noninhalation studies will be tracked as potential supplemental material.) PFDA mixture studies are included if they employ an experimental arm that involves exposure to a single PFDA. (Note: Other PFDA mixture studies are tracked as potential supplemental material.); Studies must address exposure to the following: PFDA (CASRN 335-76-2), or PFDA ammonium salt (CASRN 3108-42-7) or PFDA sodium salt (CASRN 3830-45-3).
Comparators | Human: A comparison or reference population exposed to lower levels (or no exposure/exposure below detection levels) or for shorter periods of time.; Animal: Includes comparisons to historical controls or a concurrent control group that is unexposed, exposed to vehicle only or air only exposures. (Note: Experiments including exposure to PFDA across different durations or exposure levels without including one of these control groups will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4 of the protocol].)
Outcomes | All cancer and noncancer health outcomes. (Note: Other than genotoxicity studies, studies including only molecular endpoints [e.g., gene or protein changes; receptor binding or activation] or other nonphenotypic endpoints addressing the potential biological or chemical progression of events contributing toward toxic effects will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4 of the protocol]). Functional immune measures (e.g., antibody responses) are considered relevant phenotypic outcomes in accordance with immunotoxicity guidance from the World Health Organization (IPCS, 2012).

In addition to those studies meeting the PECO criteria and studies excluded as not relevant to the assessment, studies containing supplemental material potentially relevant to the specific aims of the assessment were inventoried during the literature screening process. Although these studies did not meet PECO criteria, they were not excluded. Rather, they were considered for use in addressing the identified key science issues (see Appendix A.2.4) and other potential scientific uncertainties identified during assessment development but unanticipated at the time of protocol posting. Studies categorized as “potentially relevant supplemental material" included the following:

- In vivo mechanistic or mode-of-action (MOA) studies, including non-PECO routes of exposure (e.g., intraperitoneal injection) and populations (e.g., nonmammalian models)
- In vitro and in silico models
- ADME and PK studies (excluding models)^8^
- Exposure assessment or characterization (no health outcome) studies
- Human case reports or case-series studies

The literature was screened by two independent reviewers with a process for conflict resolution, first at the title-and-abstract level and subsequently the full-text level, using structured forms in DistillerSR (Evidence Partners; https://distillercer.com/products/distillersr-systematic-review-software/). Literature inventories for PECO-relevant studies and studies tagged as “potentially relevant supplemental material" during screening were created to facilitate subsequent review of individual studies or sets of studies by topic-specific experts.

### 1.2.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiologic and animal toxicological studies used in the PFDA assessment are provided in the systematic review protocol (see Appendix A). The general approach for evaluating PECO-relevant health effect studies is the same for epidemiology and animal toxicological studies, although the specifics of applying the approach differ; thus, they are described in detail in Appendices A.6.2 and A.6.3, respectively. Approaches for study evaluation for mechanistic studies are described in detail in Appendix A.6.5.

The key concerns for the review of epidemiology and animal toxicological studies are potential bias (systematic errors or deviations from the truth related to internal validity that affect the magnitude or direction of an effect in either direction) and insensitivity (factors that limit the ability of a study to detect a true effect and can lead to a false negative). For example, any types of random measurement error that may lead to attenuation of study results (i.e., bias toward the null). In evaluating individual studies, two or more reviewers independently arrived at judgments regarding the reliability of the study results (reflected as study confidence determinations; see below) regarding each outcome or outcome grouping of interest; thus, different judgments were possible for different outcomes within the same study. The results of these reviews were tracked within EPA’s version of the Health Assessment Workplace Collaborative (HAWC (https://hawc.epa.gov/assessment/100500072/)). To develop these judgments, each reviewer assigned a rating of good, adequate, deficient (or not reported, which generally carried the same functional interpretation as deficient), or critically deficient (listed from best to worst methodological conduct; see Appendix A.6 for definitions) related to each evaluation domain representing the different characteristics of the study methods that were evaluated based on the criteria outlined in HAWC.

Once all evaluation domains were evaluated, the identified strengths and limitations were collectively considered by the reviewers to reach a final study confidence classification:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely to be of a notable degree or to have a notable impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight than high or medium confidence results during evidence synthesis and integration (see Sections 1.2.4 and 1.2.5).
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Using the HAWC platform, the two reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination with conflict resolution by an additional reviewer, as needed. The specific limitations identified during study evaluation were carried forward to inform the synthesis (see Section 1.2.4) within each body of evidence for a given health effect.

### 1.2.3 Additional Epidemiology Considerations

While the detailed methods for epidemiology study evaluation are described in the systematic review protocol (see Appendix A.6.2.1), a few considerations that have been developed further are described in this section.

As noted above, study sensitivity is an important consideration given that it could lead to a false negative (i.e., null) result (Type II error) if a study is underpowered or not designed with adequate sensitivity to detect an association that may exist. A key element for study sensitivity, along with others described in the systematic review protocol, is whether exposure contrasts/gradients are sufficient across populations to detect differences in risk. For example, measurement errors that result in inaccurate exposure estimates can lead to exposure misclassification but can also influence the ability to detect an association or an exposure-response relationship, which may be evidence of a biologic gradient.

Confounding across PFAS is a potential source of uncertainty when interpreting the results of epidemiology studies of individual PFAS (e.g., quantifying the effect of an individual PFAS can potentially be confounded by other PFAS). For confounding to occur, copollutants would have to be associated with PFAS of interest, associated with the endpoint, and not act as an intermediate in the causal pathway. One way to begin to assess whether coexposure is occurring is through examination of correlations. In a preliminary analysis of 22 studies in the inventory reporting correlations, correlations differed across the PFAS (see Appendix A.6, Figure 6-2). While some pairs have correlation coefficients consistently above 0.6 (e.g., PFNA and PFDA), the correlations for most vary from 0.1 to 0.6 depending on the study. For this reason, it was not considered appropriate to assume that coexposure to other PFAS was necessarily an important confounder in all studies. The potential for confounding across PFAS is incorporated in individual study evaluations and assessed across studies in evidence synthesis. In most studies, it is difficult to determine the likelihood of confounding without considering additional information not typically included in individual study evaluation (e.g., associations of other PFAS with the outcome of interest and correlation profiles of PFAS within and across studies). In addition, even when this information is considered or the study authors perform analyses to adjust for other PFAS, it is often not possible to fully disentangle the associations due to high correlations. This stems from the potential for amplification bias in which bias can occur following adjustment of highly correlated PFAS (Weisskopf et al., 2018). Thus, in most studies, there may be some residual uncertainty about the risk of confounding by other PFAS. A “Good" rating for the confounding domain is reserved for situations in which concern is minimal for substantial confounding across PFAS as well as other sources of confounding. Examples of this situation include results for a PFAS that predominates in a population (such as a contamination event) or studies that demonstrate robust results following multi-PFAS adjustment, which would also indicate minimal concern for amplification bias. Because of the challenge in evaluating individual studies for confounding across PFAS, this issue is also assessed across studies during the evidence synthesis phase (as described in the systematic review protocol; Appendix A, Section 9), primarily when there is support for an association with adverse health effects in the epidemiological evidence (i.e., moderate, or robust evidence in humans, as described below). Analyses used include comparing results across studies in populations with different PFAS exposure mixture profiles, considering results of multipollutant models when available, and examining strength of associations for other correlated PFAS. In situations in which there is considerable uncertainty regarding the impact of residual confounding across PFAS, it is captured as a factor that decreases the overall strength of evidence (see Appendix A.10).

### 1.2.4 Data Extraction

The detailed data extraction approach is provided in Appendix A.8. Briefly, data extraction and content management were carried out using HAWC for all health effects for animal studies and some health effects for epidemiological studies (for which data visualizations were necessary to understanding the evidence synthesis judgments). Data extraction elements that were collected from epidemiological, animal toxicological, and in vitro studies is described in HAWC (https://hawcprd.epa.gov/about/). Not all studies that meet the PECO criteria went through data extraction: Studies evaluated as being uninformative were not used to inform assessment judgments and therefore did not undergo full data extraction. All findings from informative studies were considered for extraction, regardless of the statistical significance of their findings. The level of extraction for specific outcomes within a study may differ (i.e., ranging from a narrative to full extraction of dose-response effect size information). For quality control, data extraction was performed by one member of the evaluation team and independently verified by at least one other member. Discrepancies in data extraction were resolved by discussion or consultation within the evaluation team.

### 1.2.5 Evidence Synthesis and Integration

For the purposes of this Toxicological Review, evidence synthesis and integration are considered distinct but related processes (see Appendix A, Sections 9 and 10 for full details). For each assessed health effect, the evidence syntheses provide a summary discussion of each body of evidence considered in the review that directly informs the integration across evidence to draw an overall judgment for each health effect. The available human and animal evidence pertaining to the potential health effects are synthesized separately, with each synthesis providing a summary discussion of the available evidence that addresses considerations regarding causation that are adapted from Hill (1965). Mechanistic evidence is also synthesized as necessary to help inform key decisions regarding the human and animal evidence; processes for synthesizing mechanistic information are covered in detail in Appendix A, Section 9.2.

The syntheses of the human and animal health effects evidence focus on describing aspects of the evidence that best inform causal interpretations, including the exposure context examined in the sets of studies. Thus, data permitting, the evidence synthesis emphasizes studies of high and medium confidence. Correspondingly, during data extraction when a relative abundance of medium and high confidence studies was available for a given health outcome the low confidence studies did not generally undergo full data extraction. Documentation of when this approach was taken is noted in the specific health effect sections. When possible, results across studies are compared using graphs and charts or other data visualization strategies. The synthesis of mechanistic information informs the integration of health effects evidence for both hazard identification (e.g., biological plausibility or coherence of the available human or animal evidence; inferences regarding human relevance, or the identification of susceptible populations and lifestages across the human and animal evidence) and dose-response evaluation (e.g., selection of benchmark response levels, selection of uncertainty factors). Evaluations of mechanistic information typically differ from evaluations of phenotypic evidence (e.g., from routine toxicological studies) primarily because mechanistic data evaluations consider the support for and involvement of specific events or sets of events within the context of a broader research question (e.g., support for a hypothesized MOA; consistency with known biological processes), rather than evaluations of individual apical endpoints considered in relative isolation.

Following the synthesis of human and animal health effects data and mechanistic data, integrated judgments are drawn across all lines of evidence for each assessed health effect. During evidence integration, a structured and documented two-step process is used, as follows:

- Building from the separate syntheses of the human and animal evidence, the strength of the evidence from the available human and animal health effect studies is summarized in parallel, but separately, using a structured evaluation of an adapted set of considerations first introduced by Sir Bradford Hill (Hill, 1965). This process is conceptually similar to that used by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) (Morgan et al., 2016; Guyatt et al., 2011; Schünemann et al., 2011), which arrives at an overall integration conclusion based on consideration of the body of evidence. These summaries incorporate the relevant mechanistic evidence (or MOA understanding) that informs the biological plausibility and coherence within the available human or animal health effect studies. The terms associated with the different strength of evidence judgments within evidence streams are robust, moderate, slight, indeterminate, and compelling evidence of no effect.
- The animal, human, and mechanistic evidence judgments are then combined to draw an overall judgment that incorporates inferences across evidence streams. Specifically, the inferences considered during this integration include the human relevance of the animal and mechanistic evidence, coherence across the separate bodies of evidence, and other important information (e.g., judgments regarding susceptibility). Note that without evidence to the contrary, the human relevance of animal findings is assumed. The final output is a summary judgment of the evidence base for each potential human health effect across evidence streams. The terms associated with these summary judgments are evidence demonstrates, evidence indicates (likely), evidence suggests, evidence inadequate, and strong evidence of no effect. The decision points within the structured evidence integration process are summarized in an evidence profile table for each considered health effect.

As discussed in the protocol (see Appendix A), the methods for evaluating the potential carcinogenicity of PFAS follow processes laid out in the EPA cancer guidelines (U.S. EPA, 2005); however, for PFDA, data relevant to cancer were sparse, which limited the extent of possible analysis (see Section 3.3).

### 1.2.6 Dose-Response Analysis

The details for the dose-response employed in this Toxicological Review can be found in Appendix A.11. Briefly, a dose-response assessment was performed for noncancer health hazards, following exposure to PFDA via the oral route, as supported by existing data. For oral noncancer hazards, oral reference doses (RfDs) are derived when possible. An RfD is an estimate, with uncertainty spanning perhaps an order of magnitude, of an exposure to the human population (including susceptible subgroups) that is likely to be without an appreciable risk of deleterious health effects over a lifetime (U.S. EPA, 2002). The derivation of a reference value like the RfD depends on the nature of the health hazard conclusions drawn during evidence integration. For noncancer outcomes, a dose-response assessment was conducted for evidence integration conclusions of evidence demonstrates or evidence indicates (likely). In general, toxicity values are not developed for noncancer hazards with evidence suggests conclusions (see Appendix A, Section 10.2 for exceptions). Consistent with EPA practice, the PFDA assessment applied a two-step approach for dose-response assessment that distinguishes analysis of the dose-response data in the range of observation from any inferences about responses at lower environmentally relevant exposure levels (U.S. EPA, 2012a, 2005):

- Within the observed dose range, the preferred approach was to use dose-response modeling to incorporate as much of the dataset as possible into the analysis. This modeling to derive a point of departure (POD) ideally includes an exposure level near the lower end of the range of observation, without significant extrapolation to lower exposure levels.
- As derivation of cancer risk estimates and reference values nearly always involves extrapolation to exposures lower than the POD; the approaches applied in these assessments are described in more detail in Section A.11.2.

When sufficient and appropriate human and laboratory animal data are available for the same outcome, human data are generally preferred for the dose-response assessment because use of human data eliminates the need to perform interspecies extrapolations. For reference values, this assessment will derive a candidate value from each suitable dataset. Evaluation of these candidate values will yield a single organ/system-specific value for each organ/system under consideration from which a single overall reference value will be selected to cover all health outcomes across all organs/systems. While this overall reference value represents the focus of these dose-response assessments, the organ/system-specific values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple PFAS (or other agents) acting at a common organ/system. For noncancer toxicity values, uncertainties in these estimates are characterized and discussed.

For dose-response purposes, EPA has developed a standard set of models (http://www.epa.gov/bmds) that can be applied to typical datasets, including those that are nonlinear. In situations in which there are alternative models with significant biological support (e.g., toxicodynamic models), those models are included as alternatives in the assessment(s) along with a discussion of the models' strengths and uncertainties. EPA has developed guidelines on modeling dose-response data, assessing model fit, selecting suitable models, and reporting modeling results (see the EPA Benchmark Dose Technical Guidance (U.S. EPA, 2012a)). For each modeled response, a POD from the observed data was estimated to mark the beginning of extrapolation to lower doses. The POD is an estimated dose (expressed in human-equivalent terms) near the lower end of the observed range without significant extrapolation to lower doses. The POD is used as the starting point for subsequent extrapolations and analyses. For noncancer effects, the POD is used in calculating the RfD.

7 This figure shows the linear structures, but the assessment may also apply to other nonlinear isomers of PFDA and related salts as described in the Executive Summary.

8 Given the known importance of ADME data, this supplemental tagging was used as the starting point for a separate screening and review of pharmacokinetics data (see Appendix A.9.2 for details).