# REFERENCES

Abe, T; Takahashi, M; Kano, M; Amaike, Y; Ishii, C; Maeda, K; Kudoh, Y; Morishita, T; Hosaka, T; Sasaki, T; Kodama, S; Matsuzawa, A; Kojima, H; Yoshinari, K. (2017). Activation of nuclear receptor CAR by an environmental pollutant perfluorooctanoic acid. Arch Toxicol 91: 2365–2374. 10.1007/s00204-016-1888-3.27832320
Adinehzadeh, M; Reo, NV. (1998). Effects of peroxisome proliferators on rat liver phospholipids: sphingomyelin degradation may be involved in hepatotoxic mechanism of perfluorodecanoic acid. Chern Res Toxicol 11: 428–440. 10.1021/tx970155t.
Adinehzadeh, M; Reo, NV; Jarnot, BM; Taylor, CA; Mattie, DR. (1999). Dose-response hapatotoxicity of the peroxisome proliferator, perfluorodecanoic acid and the relationship to phospholipid metabolism in rats. Toxicology 134:179–195. 10.1016/S0300-483X(99)00038-4.10403636
Agarwal, S; Cunningham-Rundles, C. (2007). Assessment and clinical interpretation of reduced IgG values. Ann Allergy Asthma Immunol 99: 281–283. 10.l016/S1081-1206(10)60665-5.17910333
Al Sharif, M; Alov, P; Vitcheva, V; Pajeva, 1; Tsakovska, I. (2014). Modes-of-action related to repeated dose toxicity: tissue-specific biological roles of PPAR y ligand-dependent dysregulation in nonalcoholic fatty liver disease [Review]. PPAR Research 2014: 432647. 10.1155/2014/432647.24772164
Ammitzbøll, C; Börnsen, L; Petersen, ER; Oturai, AB; Søndergaard, HB; Grandjean, P; Sellebjerg, F. (2019). Perfluorinated substances, risk factors for multiple sclerosis and cellular immune activation. J Neuroimmunol 330: 90–95. 10.1016/j.jneuroim.2019.03.002.30852181
Amstutz, VH; Cengo, A; Gehres, F; Sijm, DTH, M; Vrolijk, MF. (2022). Investigating the cytotoxicity of per- and polyfluoroalkyl substances in HepG2 cells: A structure-activity relationship approach. Toxicology 480:153312. 10.1016/j.tox.2022.153312.36075290
Ananth, CV; Schisterman, EF. (2017). Confounding, causality, and confusion: the role of intermediate variables in interpreting observational studies in obstetrics. Am J Obstet Gynecol 217: 167–175. 10.1016/i.ajog.2017.04.016.28427805
Angrish, MM; Kaiser, JP; Mcqueen, CA; Chorley, BN. (2016). Tipping the balance: Hepatotoxicity and the 4 apical key events of hepatic steatosis [Review]. Toxicol Sci 150: 261–268. 10.1093/toxsci/kfw018.26980302
Arand, M; Coughtrie, MW; Burchell, B; Oesch, F; Robertson, LW. (1991). Selective induction of bilirubin UDP-glucuronosyl-transferase by perfluorodecanoic acid. Chern Biol Interact 77: 97–105. 10.1016/0009-2797(91)90008-U.
Arrebola, JP; Ramos, JJ; Bartolomé, M; Esteban, M; Huetos, O; Cañas, Al; López-Herranz, A; Calvo, E; Pérez-Gómez, B; Castaño, A; BIOAMBIENT.ES. (2019). Associations of multiple exposures to persistent toxic substances with the risk of hyperuricemia and subclinical uric acid levels in BIOAMBIENT.ES study. Environ Int 123: 512–521. 10.1016/j.envint.2018.12.030.30622076
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Toxicological profile for perfluoroalkyls. Draft for public comment [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/toxprofiles/tp200.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Averina, M; Brox, J; Huber, S; Furberg, AS; Sørensen, M. (2019). Serum perfluoroalkyl substances (PFAS) and risk of asthma and various allergies in adolescents. The Tromsø study Fit Futures in Northern Norway. Environ Res 169: 114–121. 10.1016/j.envres.2018.ll.005.30447498
Bao, J; Shao, LX; Liu, Y; Cui, SW; Wang, X; Lu, GL; Wang, X; Jin, YH. (2022). Target analysis and suspect screening of per- and polyfluoroalkyl substances in paired samples of maternal serum, umbilical cord serum, and placenta near fluorochemical plants in Fuxin, China. Chemosphere 307:135731. 10.1016/i.chemosphere.2022.135731.35843426
Barish, GD; Narkar, VA; Evans, RM. (2006). PPAR delta: a dagger in the heart of the metabolic syndrome. J Clin Invest 116: 590–597. 10.1172/JCI27955.16511591
Bashir, T; Obeng-Gyasi, E. (2022). The Association between Multiple Per- and Polyfluoroalkyl Substances' Serum Levels and Allostatic Load. Int J Environ Res Public Health 19. 10.3390/ijerph19095455.
Betancourt, MJ; Girolami, M. (2013). Hamiltonian monte carlo for hierarchical models. Betancourt, MJ; Girolami, M. 10.48550/arXiv.1312.0906.
Bjerregaard-Olesen, C; Bossi, R; Bech, BH; Bonefeld-Jørgensen, EC. (2014). Extraction of perfluorinated alkyl acids from human serum for determination of the combined xenoestrogenic transactivity: A method development. Chemosphere 129: 232–238. 10.1016/j.chemosphere.2014.08.071.25234096
Bjerregaard-Olesen, C; Ghisari, M; Bonefeld-Jørgensen, EC. (2016). Activation of the estrogen receptor by human serum extracts containing mixtures of perfluorinated alkyl acids from pregnant women. Environ Res 151: 71–79. 10.1016/j.envres.2016.07.001.27451001
Blomberg, AJ; Norén, E; Haug, LS; Lindh, C; Sabaredzovic, A; Pineda, D; Jakobsson, K; Nielsen, C. (2023). Estimated transfer of perfluoroalkyl substances (pfas) from maternal serum to breast milk in women highly exposed from contaminated drinking water: A study in the Ronneby mother-child cohort. Environ Health Perspect 13. 10.1289/EHP11292.
Boobis, AR; Doe, JE; Heinrich-Hirsch, B; Meek, ME; Munn, S; Ruchirawat, M; Schlatter, J; Seed, J; Vickers, C. (2008). IPCS framework for analyzing the relevance of a noncancer mode of action for humans [Review]. Crit Rev Toxicol 38: 87–96. 10.1080/104084407Q1749421.18259981
Borges, T; Glauert, HP; Chen, LC; Chow, CK; Robertson, LW. (1990). Effect of the peroxisome proliferator perfluorodecanoic acid on growth and lipid metabolism in Sprague Dawley rats fed three dietary levels of selenium. Arch Toxicol 64: 26–30. 10.1007/BF01973372.2306190
Borges, T; Glauert, HP; Robertson, LW. (1993). Perfluorodecanoic acid noncompetitively inhibits the peroxisomal enzymes enoyl-CoA hydratase and 3-hydroxyacyl-CoA dehydrogenase. Toxicol Appl Pharmacol 118: 8–15. 10.1006/taap.1993.1003.8430427
Borges, T; Robertson, LW; Peterson, RE; Glauert, HP. (1992). Dose-related effects of perfluorodecanoic acid on growth, feed intake and hepatic peroxisomal beta-oxidation. Arch Toxicol 66: 18–22. 10.1007/BF02307265.1580792
Borghese, MM; Liang, CL; Owen, J; Fisher, M. (2022). Individual and mixture associations of perfluoroalkyl substances on liver function biomarkers in the Canadian Health Measures Survey. Environ Health 21: 85. 10.1186/s12940-022-00892-6.36104725
Bretveld, RW; Thomas, CMG; Scheepers, PTJ; Zielhuis, GA; Roeleveld, N. (2006). Pesticide exposure: the hormonal function of the female reproductive system disrupted? [Review]. Reprod Biol Endocrinol 4: 30. 10.1186/1477-7827-4-30.16737536
Brewster, DW; Birnbaum, LS. (1989). The biochemical toxicity of perfluorodecanoic acid in the mouse is different from that of 2, 3, 7, 8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 99: 544–554. 10.1016/0041-008X(89)90161-0.2749739
Brosset, E; Ngueta, G. (2022). Exposure to per- and polyfluoroalkyl substances and glycemic control in older US adults with type 2 diabetes mellitus. Environ Res 216:114697. 10.1016/j.envres.2022.114697.36334831
Buck Louis, GM; Sundaram, R; Schisterman, EF; Sweeney, AM; Lynch, CD; Gore-Langton, RE; Maisog, J; Kim, S; Chen, Z; Barr, DB. (2013). Persistent environmental pollutants and couple fecundity: The LIFE study. Environ Health Perspect 121: 231–236. 10.1289/ehp.1205301.23151773
Buck Louis, GM; Zhai, S; Smarr, MM; Grewal, J; Zhang, C; Grantz, KL; Hinkle, SN; Sundaram, R; Lee, S; Honda, M; Oh, J; Kannan, K. (2018). Endocrine disruptors and neonatal anthropometry, NICHD Fetal Growth Studies - Singletons. Environ Int 119: 515–526. 10.1016/i.envint.2018.07.024.30055518
Budtz-Jørgensen, E; Grandjean, P. (2018a). Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity. PLoS ONE 13: e0205388. 10.1371/journal.pone.0205388.30339706
Budtz-Jørgensen, E; Grandjean, P. (2018b). Computational details for the paper “Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity".
Buhrke, T; Kibellus, A; Lampen, A. (2013). In vitro toxicological characterization of perfluorinated carboxylic acids with different carbon chain lengths. Toxicol Lett 218: 97–104. 10.1016/j.toxlet.2013.01.025.23391484
Butenhoff, JL; Bjork, JA; Chang, SC; Ehresman, DJ; Parker, GA; Das, K; Lau, C; Lieder, PH; van Otterdijk, FM; Wallace, KB. (2012). Toxicological evaluation of ammonium perfluorobutyrate in rats: twenty-eight-day and ninety-day oral gavage studies. Reprod Toxicol 33: 513–530. 10.1016/j.reprotox.2011.08.004.21878386
Cai, Y; Appelkvist, EL; Depierre, JW. (1995). Hepatic oxidative stress and related defenses during treatment of mice with acetylsalicylic acid and other peroxisome proliferators. J Biochem Toxicol 10: 87–94. 10.1002/jbt.2570100205.7562957
Cao, L; Guo, Y; Chen, Y; Hong, J; Wu, J; Hangbiao, J. (2022). Per-/polyfluoroalkyl substance concentrations in human serum and their associations with liver cancer. Chemosphere 296: 134083. 10.1016/i.chemosphere.2022.134083.35216980
Cao, L; Quan, XB; Zeng, WJ; Yang, XO; Wang, MJ. (2016). Mechanism of hepatocyte apoptosis [Review]. Journal of Cell Death 9: 19–29. 10.4137/JCD.S39824.28058033
Cattley, RC; Cullen, JM. (2018). Chapter 8. Liver and gall bladder. In MA Wallig; WM Haschek; CG Rousseaux; B Bolon (Eds.). Fundamentals of toxicologic pathology (3rd ed., pp. 125–151). Cambridge, MA: Academic Press. 10.1016/B978-0-12-8Q98417.00008-3.
Cellesi, C; Michelangeli, C; Rossolini, GM; Giovannoni, F; Rossolini, A. (1989). Immunity to diphtheria, six to 15 years after a basic three-dose immunization schedule. Journal of Biological Standardization 17: 29–34. 10.1016/0092-1157(89)90025-5.2921251
Chang, CJ; Barr, DB; Ryan, PB; Panuwet, P; Smarr, MM; Liu, K; Kannan, K; Yakimavets, V; Tan, Y; Ly, V; Marsit, CJ; Jones, DP; Corwin, EJ; Dunlop, AL; Liang, D. (2022). Per- and polyfluoroalkyl substance (PFAS) exposure, maternal metabolomic perturbation, and fetal growth in African American women: A meet-in-the-middle approach. Environ Int 158: 106964. 10.1016/j.envint.2021.106964.34735953
Chapman, AB; Abraham, WT; Zamudio, S; Coffin, C; Merouani, A; Young, D; Johnson, A; Osorio, F; Goldberg, C; Moore, LG; Dahms, T; Schrier, RW. (1998). Temporal relationships between hormonal and hemodynamic changes in early human pregnancy. Kidney Int 54: 2056–2063. 10.1046/j.1523-1755.1998.00217.x.9853271
Chen, H; Huang, CY; Wilson, MW; Lay, LT; Robertson, LW; Chow, CK; Glauert, HP. (1994). Effect of the peroxisome proliferators ciprofibrate and perfluorodecanoic acid on hepatic cell proliferation and toxicity in Sprague-Dawley rats. Carcinogenesis 15: 2847–2850. 10.1093/carcin/15.12.2847.8001245
Chen, L; Tong, C; Huo, X; Zhang, J; Tian, Y. (2021). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and birth outcomes: A longitudinal cohort with repeated measurements. Chemosphere 267:128899. 10.1016/j.chemosphere.2020.128899.33220988
Chen, LC; Tatum, V; Glauert, HP; Chow, CK. (2001). Peroxisome proliferator perfluorodecanoic acid alters glutathione and related enzymes. J Biochem Mol Toxicol 15:107–113. 10.1002/jbt.6.11284052
Chen, X; Feng, X; Sun, X; Li, Y; Yang, Y; Shan, G; Zhu, L. (2022). Quantifying indirect contribution from precursors to human body burden of legacy PFASs based on paired blood and oneweek duplicate diet. Environ Sci Technol 56: 5632–5640. 10.1021/acs.est.1c07465.35417148
Cheng, X; Klaassen, CD. (2008a). Critical role of PPAR-alpha in perfluorooctanoic acid- and perfluorodecanoic acid-induced downregulation of Oatp uptake transporters in mouse livers. Toxicol Sci 106: 37–45. 10.1093/toxsci/kfn161.18703564
Cheng, X; Klaassen, CD. (2008b). Perfluorocarboxylic acids induce cytochrome P450 enzymes in mouse liver through activation of PPAR-alpha and CAR transcription factors. Toxicol Sci 106: 29–36. 10.1093/toxsci/kfn147.18648086
Chinje, E; Kentish, P; Jarnot, B; George, M; Gibson, G. (1994). Induction of the CYP4A subfamily by perfluorodecanoic acid: The rat and the guinea pig as susceptible and nonsusceptible species. Toxicol Lett 71: 69–75. 10.1016/03784274(94)90200-3.8140591
Choi, G; Buckley, JP; Kuiper, JR; Keil, AP. (2022). Log-transformation of Independent Variables: Must We? Epidemiology 33: 843–853. 10.1097/EDE.0000000000001534.36220581
Christensen, KY; Raymond, MR; Thompson, BA; Anderson, HA. (2016). Fish consumption, levels of nutrients and contaminants, and endocrine-related health outcomes among older male anglers in Wisconsin. J Occup Environ Med 58: 668–675. 10.1097/JOM.0000000000000758.27253230
Christenson, B; Böttiger, M. (1986). Serological immunity to diphtheria in Sweden in 1978 and 1984. Scand J Infect Dis 18: 227–233. 10.3109/00365548609032331.3738433
Cohen, NJ; Yao, M; Midya, V; India-Aldana, S; Mouzica, T; Andra, SS; Narasimhan, S; Meher, AK; Arora, M; Chan, JKY; Chan, SY; Loy, SL; Minguez-Alarcon, L; Oulhote, Y; Huang, J; Valvi, D. (2023). Exposure to perfluoroalkyl substances and women's fertility outcomes in a Singaporean population-based preconception cohort. Sci Total Environ 873:162267. 10.1016/j.scitotenv.2023.162267.36801327
Colicino, E; Pedretti, NF; Busgang, SA; Gennings, C. (2020). Per-and poly-fluoroalkyl substances and bone mineral density: Results from the Bayesian weighted quantile sum regression. Environmental Epidemiology 4: 1. 10.1097/EE9.0000000000000092.
Collier, RJ. (1975). Diphtheria toxin: Mode of action and structure [Review]. Bacteriol Rev 39: 54–85. 10.1128/br.39.1.54-85.1975.164179
Corton, JC; Peters, JM; Klaunig, JE. (2018). The PPARα-dependent rodent liver tumor response is not relevant to humans: addressing misconceptions [Review]. Arch Toxicol 92: 83–119. 10.1007/s00204-017-2094-7.29197930
Crump, KS. (1995). Calculation of benchmark doses from continuous data. Risk Anal 15: 79–89. 10.1111/i.1539-6924.1995.tb00095.x.
Cui, F; Liu, H; Li, Y; Zheng, TZ; Xu, S; Xia, W; Sheng, X. (2022). Association of exposure to perand polyfluoroalkyl substances with hemoglobin and hematocrit during pregnancy. Ecotoxicol Environ Saf 248:114319. 10.1016/i.ecoenv.2022.114319.36423372
Davis, JW; Vanden Heuvel, JP; Peterson, RE. (1991). Effects of perfluorodecanoic acid on de novo fatty acid and cholesterol synthesis in the rat. Lipids 26: 857–859. 10.1007/BF02536170.1795607
Derakhshan, A; Kortenkamp, A; Shu, H; Broeren, MAC; Lindh, CH; Peeters, RP; Bornehag, CG; Demeneix, B; Korevaar, TIM. (2022). Association of per- and polyfluoroalkyl substances with thyroid homeostasis during pregnancy in the SELMA study. Environ Int 167: 107420. 10.1016/j.envint.2022.107420.35870378
Derbel, M; Hosokawa, M; Satoh, T. (1996). Differences in the induction of carboxylesterase RL4 in rat liver microsomes by various perfluorinated fatty acids, metabolically inert derivatives of fatty acids. Biol Pharm Bull 19: 765–767. 10.1248/bpb.19.765.
DeWitt, JC; Germolec, DR; Luebke, RW; Johnson, VJ. (2016). Associating Changes in the Immune System with Clinical Diseases for Interpretation in Risk Assessment. Current Protocols in Toxicology 67: 1.1–18.11.22. 10.1002/0471140856.tx1801s67.
Ding, J; Dai, Y; Zhang, J; Wang, Z; Zhang, L; Xu, S; Tan, R; Guo, J; Qi, X; Chang, X; Wu, C; Zhou, Z. (2022). Associations of perfluoroalkyl substances with adipocytokines in umbilical cord serum: A mixtures approach. Environ Res 216:114654. 10.1016/i.envres.2022.114654.36309220
Division of Environmental Epidemiology, I, forRAS; Portengen, L; Rignell-Hydbom, A; Jönsson, B, oAG; Lindh, CH; Piersma, AH; Toft, G; Bonde, JP; Heederik, D; Rylander, L; Vermeulen, R. (2016). Prenatal Phthalate, Perfluoroalkyl Acid, and Organochlorine Exposures and Term Birth Weight in Three Birth Cohorts: Multi-Pollutant Models Based on Elastic Net Regression. Environ Health Perspect 124: 365–372.26115335
Donat-Vargas, C; Bergdahl, IA; Tornevi, A; Wennberg, M; Sommar, J; Kiviranta, H; Koponen, J; Rolandsson, O; Åkesson, A. (2019a). Perfluoroalkyl substances and risk of type II diabetes: A prospective nested case-control study. Environ Int 123: 390–398. 10.1016/i.envint.2018.12.026.30622063
Donat-Vargas, C; Bergdahl, IA; Tornevi, A; Wennberg, M; Sommar, J; Koponen, J; Kiviranta, H; Akesson, A. (2019b). Associations between repeated measure of plasma perfluoroalkyl substances and cardiometabolic risk factors. Environ Int 124: 58–65. 10.1016/i.envint.2019.01.007.30639908
Duan, Y; Sun, H; Yao, Y; Li, Y; Meng, Y; Lu, Y; Han, L; Chen, L (2021). Serum concentrations of per-/polyfluoroalkyl substances and risk of type 2 diabetes: A case-control study. Sci Total Environ 787: 147476. 10.1016/i.scitotenv.2021.147476.33992947
Dufour, P; Pirard, C; Petrossians, P; Beckers, A; Charlier, C. (2020). Association between mixture of persistent organic pollutants and thyroid pathologies in a Belgian population. Environ Res 181: 108922. 10.1016/i.envres.2019.108922.31759644
Dunder, L; Salihovic, S; Elmståhl, S; Lind, PM; Lind, L. (2023). Associations between per- and polyfluoroalkyl substances (PFAS) and diabetes in two population-based cohort studies from Sweden. J Expo Sci Environ Epidemiol 33: 748–756. 10.1038/s41370-023-00529-x.36964247
Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Gibbs, ST; Granville, CA; Blystone, CR. (2019). Toxicokinetics of perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA) and perfluorodecanoic acid (PFDA) in male and female Hsd:Sprague dawley SD rats following intravenous or gavage administration. Xenobiotica 50: 1–11. 10.1080/00498254.2019.1683776.31625424
Dzierlenga, M, .W.; Crawford, L, .; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Edwards, SW; Tan, YM; Villeneuve, DL; Meek, ME; McQueen, CA. (2016). Adverse outcome pathways—Organizing toxicological information to improve decision making [Review]. J Pharmacol Exp Ther 356: 170–181. 10.1124/jpet.115.228239.26537250
Eick, SM; Demicco, E; Valeri, L; Woodruff, TJ; Morello-Frosch, R; Hom Thepaksorn, EK; Izano, MA; Cushing, U; Wang, Y; Smith, SC; Gao, S; Park, JS; Padula, AM. (2020). Associations between prenatal maternal exposure to per- and polyfluoroalkyl substances (PFAS) and polybrominated diphenyl ethers (PBDEs) and birth outcomes among pregnant women in San Francisco. Environ Health 19: 100-100. 10.1186/s12940-02000654-2.32938446
Ericson, I; Goómez, M; Nadal, M; van Bavel, B; Lindström, G; Domingo, JL. (2007). Perfluorinated chemicals in blood of residents in Catalonia (Spain) in relation to age and gender: a pilot study. Environ Int 33: 616–623. 10.1016/i.envint.2007.01.003.17289145
Evans, N; Conley, JM; Cardon, M; Hartig, P; Medlock-Kakaley, E; Gray, LE, Jr. (2022). In vitro activity of a panel of per- and polyfluoroalkyl substances (PFAS), fatty acids, and pharmaceuticals in peroxisome proliferator-activated receptor (PPAR) alpha, PPAR gamma, and estrogen receptor assays. Toxicol Appl Pharmacol 449:116136. 10.1016/j.taap.2022.116136.35752307
Fabrega, F; Kumar, V; Benfenati, E; Schuhmacher, M; Domingo, JL; Nadal, M. (2015). Physiologically based pharmacokinetic modeling of perfluoroalkyl substances in the human body. Toxicol Environ Chern 97: 814–827. 10.1080/02772248.2015.1060976.
Feghali, M; Venkataramanan, R; Caritis, S. (2015). Pharmacokinetics of drugs in pregnancy. Semin Perinatol 39: 512–519. 10.1053/j.semperi.2015.08.003.26452316
Feng, Y; Bai, Y; Lu, Y; Chen, M; Fu, M; Guan, X; Cao, Q; Yuan, F; Jie, J; Li, M; Meng, H; Wang, C; Hong, S; Zhou, Y; Zhang, X; He, M; Guo, H. (2022a). Plasma perfluoroalkyl substance exposure and incidence risk of breast cancer: A case-cohort study in the DongfengTongji cohort. Environ Pollut 306:119345. 10.1016/j.envpol.2022.119345.35472559
Feng, Y; Fu, M; Guan, X; Wang, C; Meng, H; Zhou, Y; He, M; Guo, H. (2022b). Associations of exposure to perfluoroalkyl substances with serum uric acid change and hyperuricemia among Chinese women: Results from a longitudinal study. Chemosphere 308:136438. 10.1016/j.chemosphere.2022.136438.36116625
Frawley, RP; Smith, M; Cesta, MF; Hayes-Bouknight, S; Blystone, C; Kissling, GE; Harris, S; Germolec, D. (2018). Immunotoxic and hepatotoxic effects of perfluoro-n-decanoic acid (PFDA) on female Harlan Sprague-Dawley rats and B6C3F1/N mice when administered by oral gavage for 28 days. J Immunotoxicol 15: 41–52. 10.1080/1547691X.2018.1445145.29514525
Fromme, H; Mosch, C; Morovitz, M; Alba-Alejandre, I; Boehmer, S; Kiranoglu, M; Faber, F; Hannibal, I; Genzel-Boroviczény, O; Koletzko, B; Völkel, W. (2010). Pre- and postnatal exposure to perfluorinated compounds (PFCs). Environ Sci Technol 44: 7123–7129. 10.1021/es101184f.20722423
Fujii, Y; Niisoe, T; Harada, KH; Uemoto, S; Ogura, Y; Takenaka, K; Koizumi, A. (2015). Toxicokinetics of perfluoroalkyl carboxylic acids with different carbon chain lengths in mice and humans. J Occup Health 57:1–12. 10.1539/joh.14-0136-OA.25422127
Galazka, A; Kardymowicz, B. (1989). Immunity against diphtheria in adults in Poland. Epidemiol Infect 103: 587–593. 10.1017/s0950268800030983.2514113
Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. (1993). The immunological basis for immunization module 2: Diphtheria. (WHO/EPI/Gen/93.11–18). Galazka, AM; Milstien, JB; Robertson, SE; Cutts, FT. http://apps.who.int/iris/bitstream/handle/10665/58891/WHO-EPI-GEN-93.12-mod2eng.pdf?sequence=38&isAllowed=y.
Gaylord, A; Berger, KI; Naidu, M; Attina, TM; Gilbert, J; Koshy, TT; Han, X; Marmor, M; Shao, Y; Giusti, R; Goldring, RM; Kannan, K; Trasande, L. (2019). Serum perfluoroalkyl substances and lung function in adolescents exposed to the World Trade Center disaster. Environ Res 172: 266–272. 10.1016/i.envres.2019.02.024.30822559
Gaylord, A; Trasande, L; Kannan, K; Thomas, KM; Lee, S; Liu, M; Levine, J. (2020). Persistent organic pollutant exposure and celiac disease: A pilot study. Environ Res 186:109439. 10.1016/j.envres.2020.109439.32409013
Gelman, A; Lee, D; Guo, L. (2015). Stan: a probabilistic programming language for bayesian inference and optimization. American Educational Research Journal 40. 10.3102/1076998615606113.
Gibson, H, .M. (1973). Plasma volume and glomerular filtration rate in pregnancy and their relation to differences in fetal growth. Br J Obstet Gynaecol 80:1067–1074. 10.1111/j.1471-0528.1973.tb02981.x.
Glauert, HP; Srinivasan, S; Tatum, VL; Chen, LC; Saxon, DM; Lay, LT; Borges, T; Baker, M; Chen, LH; Robertson, LW; Chow, CK. (1992). Effects of the peroxisome proliferators ciprofibrate and perfluorodecanoic acid on hepatic cellular antioxidants and lipid peroxidation in rats. Biochem Pharmacol 43:1353–1359. 10.1016/0006-2952(92)90513-1.1562286
Glynn, A; Berger, U; Bignert, A; Ullah, S; Aune, M; Lignell, S; Darnerud, PO. (2012). Perfluorinated alkyl acids in blood serum from primiparous women in Sweden: serial sampling during pregnancy and nursing, and temporal trends 1996–2010. Environ Sci Technol 46: 9071–9079. 10.1021/es301168c.22770559
Glynn, A; Kotova, N; Dahlgren, E; Lindh, C; Jakobsson, K; Gyllenhammar, I; Lignell, S; Nalsen, C. (2020). Determinants of serum concentrations of perfluoroalkyl acids (PFAAs) in school children and the contribution of low-level PFAA-contaminated drinking water. Environ Sci Process Impacts 22: 930–944. 10.1039/c9em00497a.32040098
Goecke-Flora, CM; Wyman, JF; Jarnot, BM; Reo, NV. (1995). Effect of the peroxisome proliferator perfluoro-n-decanoic acid on glucose transport in the isolated perfused rat liver. Chern Res Toxicol 8: 77–81. 10.1021/tx00043a010.
Goecke, CM; Jarnot, BM; Reo, NV. (1994). Effects of the peroxisome proliferator perfluoro-ndecanoic acid on hepatic gluconeogenesis and glycogenesis: a 13C NMR investigation. Chern Res Toxicol 7: 15–22. 10.1021/tx00037a003.
Goeden, HM; Greene, CW; Jacobus, JA. (2019). A transgenerational toxicokinetic model and its use in derivation of Minnesota PFOA water guidance. J Expo Sci Environ Epidemiol 29: 183–195. 10.1038/s41370-018-0110-5.30631142
Goldey, ES; Crofton, KM. (1998). Thyroxine replacement attenuates hypothyroxinemia, hearing loss, and motor deficits following developmental exposure to Aroclor 1254 in rats. Toxicol Sci 45: 94–105. 10.1006/toxs.1998.2495.9848116
Goldman, JM; Murr, AS; Cooper, RL. (2007). The rodent estrous cycle: Characterization of vaginal cytology and its utility in toxicological studies [Review]. Birth Defects Res B Dev Reprod Toxicol 80: 84–97. 10.1002/bdrb.20106.17342777
Goodrich, JA; Walker, D; Lin, X; Wang, H; Lim, T; McConnell, R; Conti, DV; Chatzi, L; Setiawan, VW. (2022). Exposure to perfluoroalkyl substances and risk of hepatocellular carcinoma in a multiethnic cohort. JHEP Rep 4: 100550. 10.1016/i.jhepr.2022.100550.36111068
Grandjean, P; Andersen, EW; Budtz-Jørgensen, E; Nielsen, F; Mølbak, K; Weihe, P; Heilmann, C. (2012). Serum vaccine antibody concentrations in children exposed to perfluorinated compounds. JAMA 307: 391–397. 10.1001/jama.2011.2034.22274686
Grandjean, P; Bateson, T. (2021). RE: Benchmark analysis for PFAS immunotoxicity. Available online at (accessed
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Timmermann, A; BudtzJørgensen, E. (2017). Estimated exposures to perfluorinated compounds in infancy predict attenuated vaccine antibody concentrations at age 5-years. J Immunotoxicol 14: 188–195. 10.1080/1547691X.2017.1360968.28805477
Gyllenhammar, l; Diderholm, B; Gustafsson, J; Berger, U; Ridefelt, P; Benskin, JP; Lignell, S; Lampa, E; Glynn, A. (2018). Perfluoroalkyl acid levels in first-time mothers in relation to offspring weight gain and growth. Environ Int 111: 191–199. 10.1016/j.envint.2017.12.002.29223808
Hack, M; Klein, NK; Taylor, HG. (1995). Long-term developmental outcomes of low birth weight infants [Review]. Future Child 5: 176–196. 10.2307/1602514.7543353
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Kuttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: A review of adaptive (adverse and non-adverse) changes—Conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hall, SM; Zhang, S; Hoffman, K; Miranda, ML; Stapleton, HM. (2022). Concentrations of per- and polyfluoroalkyl substances (PFAS) in human placental tissues and associations with birth outcomes. Chemosphere 295:133873. 10.1016/j.chemosphere.2022.133873.35143854
Han, CY. (2018). Update on FXR Biology: Promising Therapeutic Target? International Journal of Molecular Sciences 19. 10.3390/ijms19072069.
Han, W; Gao, Y; Yao, Q; Yuan, T; Wang, Y; Zhao, S; Shi, R; Bonefeld-Jorgensen, EC; Shen, X; Tian, Y. (2018). Perfluoroalkyl and polyfluoroalkyl substances in matched parental and cord serum in Shandong, China. Environ Int 116: 206–213. 10.1016/j.envint.2018.04.025.29698897
Harris, MH; Rifas-Shiman, SL; Calafat, AM; Ye, X; Mora, AM; Webster, TF; Oken, E; Sagiv, SK. (2017). Predictors of per- and polyfluoroalkyl substance (PFAS) plasma concentrations in 6–10 year old American children. Environ Sci Technol 51: 5193–5204. 10.1021/acs.est.6b05811.28325044
Harris, MW; Birnbaum, LS. (1989). Developmental toxicity of perfluorodecanoic acid in C57BL/6N mice. Fundam Appl Toxicol 12: 442–448. 10.1016/0272-0590(89)90018-3.2731659
Harrison, EH; Lane, JS; Luking, S; Van Rafelghem, MJ; Andersen, ME. (1988). Perfluoro-ndecanoic acid: Induction of peroxisomal beta-oxidation by a fatty acid with dioxin-like toxicity. Lipids 23: 115–119. 10.1007/BF02535290.3367697
Haug, M; Dunder, L; Lind, PM; Lind, L; Salihovic, S. (2023). Associations of perfluoroalkyl substances (PFAS) with lipid and lipoprotein profiles. J Expo Sci Environ Epidemiol 33: 757–765. 10.1038/s41370-023-00545-x.37019983
Hpjsager, FD; Andersen, M; Juul, A; Nielsen, F; Möller, S; Christensen, HT; Grøntved, A; Grandjean, P; Jensen, TK. (2022). Prenatal and early postnatal exposure to perfluoroalkyl substances and bone mineral content and density in the Odense child cohort. Environ Int 167: 107417. 10.1016/j.envint.2022.107417.35914335
Holder, C; Deluca, N; Luh, J; Alexander, P; Minucci, JM; Vallero, DA; Thomas, K; Cohen Hubal, EA. (2023). Systematic evidence mapping of potential exposure pathways for per- and polyfluoroalkyl substances based on measured occurrence in multiple media [Review], Environ Sci Technol 57: 5107–5116. 10.1021/acs.est.2c07185.36940151
Hong, A; Zhuang, L; Cui, W; Lu, Q; Yang, P; Su, S; Wang, B; Zhang, G; Chen, D. (2022). Per- and polyfluoroalkyl substances (PFAS) exposure in women seeking in vitro fertilizationembryo transfer treatment (IVF-ET) in China: Blood-follicular transfer and associations with IVF-ET outcomes. Sci Total Environ 838: 156323. 10.1016/j.scitotenv.2022.156323.35636536
Hood, A; Klaassen, CD. (2000). Differential effects of microsomal enzyme inducers on in vitro thyroxine (T4) and triiodothyronine (T3) glucuronidation. Toxicol Sci 55: 78–84. 10.1093/toxsci/55.1.78.10788562
Hu, J; Li, J; Wang, J; Zhang, A; Dai, J. (2014). Synergistic effects of perfluoroalkyl acids mixtures with J-shaped concentration-responses on viability of a human liver cell line. Chemosphere 96: 81–88. 10.1016/j.chemosphere.2013.07.033.23942018
Huang, CY; Wilson, MW; Lay, LT; Chow, CK; Robertson, LW; Glauert, HP. (1994). Increased 8hydroxydeoxyguanosine in hepatic DNA of rats treated with the peroxisome proliferators ciprofibrate and perfluorodecanoic acid. Cancer Lett 87: 223–228. 10.1016/0304-3835(94)90226-7.7812944
Huo, X; Huang, R; Gan, Y; Luo, K; Aimuzi, R; Nian, M; Ao, J; Feng, L; Tian, Y; Wang, W; Ye, W; Zhang, J. (2020). Perfluoroalkyl substances in early pregnancy and risk of hypertensive disorders of pregnancy: A prospective cohort study. Environ Int 138:105656. 10.1016/j.envint.2020.105656.32222612
Ikeda, T; Aiba, K; Fukuda, K; Tanaka, M. (1985). The induction of peroxisome proliferation in rat liver by perfluorinated fatty acids, metabolically inert derivatives of fatty acids. J Biochem 98: 475–482. 10.1093/oxfordjournals.ibchem.a135302.4066651
Intrasuksri, U; Feller, DR. (1991). Comparison of the effects of selected monocarboxylic, dicarboxylic and perfluorinated fatty acids on peroxisome proliferation in primary cultured rat hepatocytes. Biochem Pharmacol 42:184–188. 10.1016/0006-2952(91)90698-5.2069591
IPCS (International Programme on Chemical Safety). (2007). Harmonization project document no. 4: Part 2: IPCS framework for analysing the relevance of a non-cancer mode of action for humans. Geneva, Switzerland: World Health Organization. http://www.who.int/ipcs/methods/harmonization/areas/cancer_mode.pdf?ua=1.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Ishibashi, H; Hirano, M; Kim, EY; Iwata, H. (2019). In vitro and in silico evaluations of binding affinities of perfluoroalkyl substances to baikal seal and human peroxisome proliferatoractivated receptor a. Environ Sci Technol 53: 2181–2188. 10.1021/acs.est.8b07273.30649875
Jaeschke, H; Mcgill, MR; Ramachandran, A. (2012). Oxidant stress, mitochondria, and cell death mechanisms in drug-induced liver injury: lessons learned from acetaminophen hepatotoxicity [Review]. Drug Metab Rev 44: 88–106. 10.3109/03602532.2011.602688.22229890
Jain, RB; Ducatman, A. (2019). Perfluoroalkyl acids and thyroid hormones across stages of kidney function. Sci Total Environ 696: 133994. 10.1016/j.scitotenv.2019.133994.31454605
Jain, RB; Ducatman, A. (2022). Associations of serum perfluoroalkyl substances with concentrations of blood manganese and selenium. Environ Sci Pollut Res Int 29: 90098–90107. 10.1007/s11356-022-22089-7.35864399
Jensen, RC; Glintborg, D; Timmermann, CAG; Nielsen, F; Boye, H; Madsen, JB; Bilenberg, N; Grandjean, P; Jensen, TK; Andersen, MS. (2022). Higher free thyroxine associated with PFAS exposure in first trimester. The Odense Child Cohort. Environ Res 212:113492. 10.1016/j.envres.2022.113492.35597289
Ji, K; Kim, S; Kho, Y; Sakong, J; Paek, D; Choi, K. (2012). Major perfluoroalkyl acid (PFAA) concentrations and influence of food consumption among the general population of Daegu, Korea. Sci Total Environ 438: 42–48. 10.1016/i.scitotenv.2012.08.007.22964400
Johnson, DR; Klaassen, CD. (2002). Regulation of rat multidrug resistance protein 2 by classes of prototypical microsomal enzyme inducers that activate distinct transcription pathways. Toxicol Sci 67:182–189. 10.1093/toxsci/67.2.182.12011477
Joshi-Barve, S; Kirpich, 1; Cave, MC; Marsano, LS; McClain, CJ. (2015). Alcoholic, nonalcoholic, and toxicant-associated steatohepatitis: Mechanistic similarities and differences [Review]. CMGH 1: 356–367. 10.1016/i.icmgh.2015.05.006.28210688
Judson, RS; Magpantav, FM; Chickarmane, V; Haskell, C; Tania, N; Taylor, J; Xia, M; Huang, R; Rotroff, DM; Filer, DL; Houck, KA; Martin, MT; Sipes, N; Richard, AM; Mansouri, K; Setzer, RW; Knudsen, TB; Crofton, KM; Thomas, RS. (2015). Integrated model of chemical perturbations of a biological pathway using 18 in vitro high throughput screening assays for the estrogen receptor. Toxicol Sci 148:137–154. 10.1093/toxsci/kfvl68.26272952
Kaiser, JP; Lipscomb, JC; Wesselkamper, SC. (2012). Putative mechanisms of environmental chemical-induced steatosis. Int J Toxicol 31: 551–563. 10.1177/1091581812466418.23197488
Kashino, l; Sasaki, S; Okada, E; Matsuura, H; Goudarzi, H; Miyashita, C; Okada, E; Ito, YM; Araki, A; Kishi, R. (2020). Prenatal exposure to 11 perfluoroalkyl substances and fetal growth: A large-scale, prospective birth cohort study. Environ Int 136:105355. 10.1016/i.envint.2019.105355.32029284
Kaur, K; Lesseur, C; Chen, L; Andra, SS; Narasimhan, S; Pulivarthi, D; Midya, V; Ma, Y; Ibroci, E; Gigase, F; Lieber, M; Lieb, W; Janevic, T; De Witte, LD; Bergink, V; Rommel, AS; Chen, J. (2023). Cross-sectional associations of maternal PFAS exposure on SARS-CoV-2 IgG antibody levels during pregnancy. Environ Res 219:115067. 10.1016/j.envres.2022.115067.36528042
Kawashima, Y; Kobayashi, H; Miura, H; Kozuka, H. (1995). Characterization of hepatic responses of rat to administration of perfluorooctanoic and perfluorodecanoic acids at low levels. Toxicology 99: 169–178. 10.1016/0300-483X(95)03027-D.7610463
Kelling, CK; Van Rafelghem, MJ; Drake, RL; Menahan, LA; Peterson, RE. (1986). Regulation of hepatic malic enzyme by perfluorodecanoic acid. J Biochem Toxicol 1: 23–37. 10.1002/jbt.2570010304.3271879
Kelling, CK; Van Rafelghem, MJ; Menahan, LA; Peterson, RE. (1987). Effects of perfluorodecanoic acid on hepatic indices of thyroid status in the rat. Biochem Pharmacol 36: 1337–1344. 10.1016/0006-2952(87)90091-8.3593420
Kim, JH; Park, HY; Jeon, JP; Kho, Y; Kim, SK; Park, MS; Hong, YC. (2015). The modifying effect of vitamin C on the association between perfluorinated compounds and insulin resistance in the Korean elderly: a double-blind, randomized, placebo-controlled crossover trial. Eur J Nutr 55: 1011–1020. 10.1007/s00394-015-0915-0.25939797
Kim, JI; Kim, BN; Lee, YA; Shin, CH; Hong, YC; Dpssing, LD; Hildebrandt, G; Lim, YH. (2023a). Association between early-childhood exposure to perfluoroalkyl substances and ADHD symptoms: A prospective cohort study. Sci Total Environ 879: 163081. 10.1016/j.scitotenv.2023.163081.36972880
Kim, K; Bennett, DH; Calafat, AM; Hertz-Picciotto, l; Shin, HM. (2020). Temporal trends and determinants of serum concentrations of per- and polyfluoroalkyl substances among Northern California mothers with a young child, 2009–2016. Environ Res 186:109491. 10.1016/i.envres.2020.109491.32361076
Kim, OJ; Kim, S; Park, EY; Oh, JK; Jung, SK; Park, S; Hong, S; Jeon, HL; Kim, HJ; Park, B; Park, B; Kim, S; Kim, B. (2023b). Exposure to serum perfluoroalkyl substances and biomarkers of liver function: The Korean national environmental health survey 2015–2017. Chemosphere 322:138208. 10.1016/i.chemosphere.2023.138208.36822523
Kim, SC; Hong, JT; Jang, SJ; Kang, WS; Yoo, HS; Yun, YP. (1998). Formation of 8oxodeoxyguanosine in liver DNA and hepatic injury by peroxisome proliferator clofibrate and perfluorodecanoic acid in rats. J Toxicol Sci 23:113–119. 10.2131/its.23.2_113.9644651
Kim, SJ; Choi, EJ; Choi, GW; Lee, YB; Cho, HY. (2019). Exploring sex differences in human health risk assessment for PFNA and PFDA using a PBPK model. Arch Toxicol 93: 311–330. 10.1007/s00204-018-2365-v.30483840
Kleinstreuer, NC; Ceger, P; Watt, ED; Martin, M; Houck, K; Browne, P; Thomas, RS; Casey, WM; Dix, DJ; Allen, D; Sakamuru, S; Xia, M; Huang, R; Judson, R. (2017). Development and validation of a computational model for androgen receptor activity. Chern Res Toxicol 30: 946–964. 10.1021/acs.chemrestox.6b00347.
Koponen, J; Winkens, K; Airaksinen, R; Berger, U; Vestergren, R; Cousins, IT; Karvonen, AM; Pekkanen.J; Kiviranta, H. (2018). Longitudinal trends of per- and polyfluoroalkyl substances in children's serum. Environ Int 121: 591–599. 10.1016/i.envint.2018.09.006.30308470
Kozuka, H; Watanabe, T; Horie, S; Yamada, J; Suga, T; Ikeda, T. (1991a). Characteristics of peroxisome proliferation: co-induction of peroxisomal fatty acid oxidation-related enzymes with microsomal laurate hydroxylase. Chern Pharm Bull (Tokyo) 39:1267–1271. 10.1248/cpb.39.1267.
Kozuka, H; Yamada, J; Horie, S; Watanabe, T; Suga, T; Ikeda, T. (1991b). Characteristics of induction of peroxisomal fatty acid oxidation-related enzymes in rat liver by drugs:Relationships between structure and inducing activity. Biochem Pharmacol 41: 617–623. 10.1016/0006-2952(91)90635-I.1997007
Kruschke, JK. (2021). Bayesian analysis reporting guidelines. Nat Hum Behav 5:1282–1291. 10.1038/s41562-021-01177-7.34400814
Kudo, N; Bandai, N; Suzuki, E; Katakura, M; Kawashima, Y. (2000). Induction by perfluorinated fatty acids with different carbon chain length of peroxisomal beta-oxidation in the liver of rats. Chern Biol Interact 124: 119–132. 10.1016/S00092797(99)00150-7.
Kudo, N; Kawashima, Y. (2003). Induction of triglyceride accumulation in the liver of rats by perfluorinated fatty acids with different carbon chain lengths: Comparison with induction of peroxisomal beta-oxidation. Biol Pharm Bull 26: 47–51. 10.1248/bpb.26.47.12520171
Kwon, EJ; Shin, JS; Kim, BM; Shah-Kulkarni, S; Park, H; Kho, YL; Park, EA; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects birth weight through GSTMI polymorphism. J Occup Environ Med 58: el98–e205. 10.1097/JOM.0000000000000739.
Langley, AE. (1990). Effects of perfluoro-n-decanoic acid on the respiratory activity of isolated rat liver mitochondria. J Toxicol Environ Health 29: 329–336. 10.1080/15287399009531395.2313742
Lee, E; Kinninger, A; Ursin, G; Tseng, C; Hurley, S; Wang, M; Wang, Y; Park, JS; Petreas, M; Deapen, D; Reynolds, P. (2020). Serum levels of commonly detected persistent organic pollutants and per- and polyfluoroalkyl substances (PFASs) and mammographic density in postmenopausal women. Int J Environ Res Public Health 17: 606. 10.3390/ijerph17020606.31963577
Lee, YA; Kim, JH; Jung, HW; Lim, YH; Bae, S; Kho, Y; Hong, YC; Shin, CH; Yang, SW. (2018). The serum concentrations of perfluoroalkyl compounds were inversely associated with growth parameters in 2-year old children. Sci Total Environ 628–629: 226–232. 10.1016/j.scitotenv.2018.02.050.
Lenters, V; Portengen, L; Rignell-Hydbom, A; Jonsson, BA; Lindh, CH; Piersma, AH; Toft, G; Bonde, JP; Heederik, D; Rylander, L; Vermeulen, R. (2016). Prenatal phthalate, perfluoroalkyl acid, and organochlorine exposures and term birth weight in three birth cohorts: multi-pollutant models based on elastic net regression. Environ Health Perspect 124: 365–372. 10.1289/ehp.1408933.26115335
Li, A; Hou, J; Fu, J; Wang, Y; Hu, Y; Zhuang, T; Li, M; Song, M; Jiang, G. (2023a). Association between serum levels of TSH and free T4 and per- and polyfluoroalkyl compounds concentrations in pregnant women. J Environ Sci 124:11–18. 10.1016/i.ies.2021.10.026.
Li, C; Ren, X; Cao, L; Qin, W; Guo, LH. (2019a). Investigation of binding and activity of perfluoroalkyl substances to the human peroxisome proliferator-activated receptor β/δ. Environ Sci Process Impacts 21:1908–1914. 10.1039/c9em00218a.31332417
Li, H; Chen, J; Jingchao, L; Yang, J; Tan, Z; Li, L; Xiao, F; An, Z; Ma, C; Liu, Y; Wang, L; Zhang, X; Guo, H. (2023b). Association of exposure to perfluoroalkyl substances and risk of the acute coronary syndrome: A case-control study in Shijiazhuang Hebei Province. Chemosphere 313:137464. 10.1016/i.chemosphere.2022.137464.36495974
Li, J; Yang, L; He, G; Wang, B; Miao, M; Ji, H; Wen, S; Cao, W; Yuan, W; Liang, H. (2022a). Association between prenatal exposure to perfluoroalkyl substances and anogenital distance in female neonates. Ecotoxicol Environ Saf 245:114130. 10.1016/j.ecoenv.2022.114130.36182800
Li, J; Yao, J; Xia, W; Dai, J; Liu, H; Pan, Y; Xu, S; Lu, S; Jin, S; Li, Y; Sun, X; Zhang, B; Zheng, T; Jiang, Y; Jing, T. (2020). Association between exposure to per- and polyfluoroalkyl substances and blood glucose in pregnant women. Int J Hyg Environ Health 230:113596. 10.1016/i.ijheh.2020.113596.32896786
Li, K; Gao, P; Xiang, P; Zhang, X; Cui, X; Ma, LQ. (2017a). Molecular mechanisms of PFOAinduced toxicity in animals and humans: Implications for health risks [Review]. Environ Int 99: 43–54. 10.1016/j.envint.2016.ll.014.27871799
Li, KM; Zhao, Q; Fan, ZY; Jia, SY; Liu, Q; Liu, FY; Liu, SL. (2022b). The toxicity of perfluorodecanoic acid is mainly manifested as a deflected immune function. Mol Biol Rep 49: 4365–4376. 10.1007/s11033-022-07272-w.35233679
Li, L; Yu, N; Wang, X; Shi, W; Liu, H; Zhang, X; Yang, L; Pan, B; Yu, H; Wei, S. (2022c). Comprehensive Exposure Studies of Per- and Polyfluoroalkyl Substances in the General Population: Target, Nontarget Screening, and Toxicity Prediction. Environ Sci Technol 56: 14617–14626. 10.1021/acs.est.2c03345.36174189
Li, M; Zeng, XW; Qian, ZM; Vaughn, MG; Sauve, S; Paul, G; Lin, S; Lu, L; Hu, LW; Yang, BY; Zhou, Y; Qin, XD; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Fu, C; Dong, GH. (2017b). Isomers of perfluorooctanesulfonate (PFOS) in cord serum and birth outcomes in China: Guangzhou Birth Cohort Study. Environ Int 102:1–8. 10.1016/j.envint.2017.03.006.28297681
Li, QQ; Huang, J; Cai, D; Chou, WC; Zeeshan, M; Chu, C; Zhou, Y; Lin, L; Ma, HM; Tang, C; Kong, M; Xie, Y; Dong, GH; Zeng, XW. (2023c). Prenatal exposure to legacy and alternative perand polyfluoroalkyl substances and neuropsychological development trajectories over the first 3 years of life. Environ Sci Technol 57: 3746–3757. 10.1021/acs.est.2c07807.36800558
Li, S; Cirillo, P; Hu, X; Tran, V; Krigbaum, N; Yu, S; Jones, DP; Cohn, B. (2019b). Understanding mixed environmental exposures using metabolomics via a hierarchical community network model in a cohort of California women in 1960's. Reprod Toxicol 92: 57–65. 10.1016/j.reprotox.2019.06.013.31299210
Li, T; Yu, RT; Atkins, AR; Downes, M; Tukey, RH; Evans, RM. (2012). Targeting the pregnane X receptor in liver injury [Review]. Expert Opin Ther Targets 16:1075–1083. 10.1517/14728222.2012.715634.22913318
Li, X; Song, F; Liu, X; Shan, A; Huang, Y; Yang, Z; Li, H; Yang, Q; Yu, Y; Zheng, H; Cao, XC; Chen, D; Chen, KX; Chen, X; Tang, NJ. (2022d). Perfluoroalkyl substances (PFASs) as risk factors for breast cancer: a case-control study in Chinese population. Environ Health 21: 83. 10.1186/s12940-022-00895-3.36085159
Liang, JL; Tiwari, T; Moro, P; Messonnier, NE; Reingold, A; Sawyer, M; Clark, TA. (2018). Prevention of pertussis, tetanus, and diphtheria with vaccines in the United States: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep 67: 1–44. 10.15585/mmwr.rr6702a1.
Liang, Y; Zhou, H; Zhang, J; Li, S; Shen, W; Lei, L. (2023). Exposure to perfluoroalkyl and polyfluoroalkyl substances and estimated glomerular filtration rate in adults: a crosssectional study based on NHANES (2017–2018). Environ Sci Pollut Res Int 30: 57931–57944. 10.1007/s11356-023-26384-9.36971931
Liao, Q; Tang, P; Fan, H; Song, Y; Liang, J; Huang, H; Pan, D; Mo, M; Leilei; Lin, M; Chen, J; Wei, H; Long, J; Shao, Y; Zeng, X; Liu, S; Huang, D; Qiu, X. (2023). Association between maternal exposure to per- and polyfluoroalkyl substances and serum markers of liver function during pregnancy in China: A mixture-based approach. Environ Pollut 323: 121348. 10.1016/j.envpol.2023.121348.36842621
Liao, Q; Tang, P; Pan, D; Song, Y; Lei, L; Liang, J; Liu, B; Lin, M; Huang, H; Mo, M; Huang, C; Wei, M; Liu, S; Huang, D; Qiu, X. (2022a). Association of serum per- and polyfluoroalkyl substances and gestational anemia during different trimesters in Zhuang ethnic pregnancy women of Guangxi, China. Chemosphere 309:136798. 10.1016/j.chemosphere.2022.136798.36220436
Liao, Q; Tang, P; Song, Y; Liu, B; Huang, H; Liang, J; Lin, M; Shao, Y; Liu, S; Pan, D; Huang, D; Qiu, X. (2022b). Association of single and multiple prefluoroalkyl substances exposure with preterm birth: Results from a Chinese birth cohort study. Chemosphere 307:135741. 10.1016/i.chemosphere.2022.135741.35863418
Lim, JJ; Suh, Y; Faustman, EM; Cui, JY. (2021). Regulation of transporters by perfluorinated carboxylic acids in HepaRG cells. Drug Metab Dispos 50: 1396–1413. 10.1124/dmd.121.000477.34857530
Lin, M; Liao, Q; Tang, P; Song, Y; Liang, J, un; Li, J; Mu, C; Liu, S; Qiu, X; Yi, R, ui; Pang, Q; Pan, D; Zeng, X; Huang, D. (2022). Association of maternal perfluoroalkyl substance exposure with postpartum haemorrhage in Guangxi, China. Ecotoxicol Environ Saf 245:114078. 10.1016/i.ecoenv.2022.114078.36137419
Lind, PM; Salihovic, S; Stubleski, J; Karrman, A; Lind, L. (2018). Changes in plasma levels of perfluoroalkyl substances (PFASs) are related to increase in carotid intima-media thickness over 10 years - a longitudinal study. Environ Health 17: 59. 10.1186/s12940-018-0403-0.29970113
Liu, H; Huang, Y; Pan, Y; Cheng, R; Li, X; Li, Y; Lu, S; Zhou, A; Dai, J; Xu, S. (2023). Associations between per and polyfluoroalkyl ether sulfonic acids and vitamin D biomarker levels in Chinese newborns. Sci Total Environ 866:161410. 10.1016/j.scitotenv.2023.161410.36621489
Liu, H; Pan, Y; Jin, S; Sun, X; Jiang, Y; Wang, Y; Ghassabian, A; Li, Y; Xia, W; Cui, Q; Zhang, B; Zhou, A; Dai, J; Xu, S. (2020a). Associations between six common per- and polyfluoroalkyl substances and estrogens in neonates of China. J Hazard Mater 407: 124378. 10.1016/i.ihazmat.2020.124378.33139105
Liu, J; Gao, X; Wang, Y; Leng, J; Li, J; Zhao, Y; Wu, Y. (2020b). Profiling of emerging and legacy per-/polyfluoroalkyl substances in serum among pregnant women in China. Environ Pollut 271: 116376. 10.1016/i.envpol.2020.116376.33383424
Liu, J; Li, J; Liu, Y; Chan, HM; Zhao, Y; Cai, Z; Wu, Y. (2011). Comparison on gestation and lactation exposure of perfluorinated compounds for newborns. Environ Int 37: 1206–1212. 10.1016/i.envint.2011.05.001.21620474
Liu, Y; Zhang, Z; Han, D; Zhao, Y; Yan, X; Cui, S. (2022). Association between environmental chemicals co-exposure and peripheral blood immune-inflammatory indicators. Front Public Health 10: 980987. 10.3389/fpubh.2022.980987.36483254
Liu, YZ; Zhang, ZP; Fu, ZW; Yang, K; Ding, N; Hu, LG; Fang, ZZ; Zhuo, X. (2019). Per- and polyfluoroalkyl substances display structure-dependent inhibition towards UDPglucuronosyltransferases. Environ Pollut 254:113093. 10.1016/i.envpol.2019.113093.31472452
Long, M; Ghisari, M; Bonefeld-Jørgensen, EC. (2013). Effects of perfluoroalkyl acids on the function of the thyroid hormone and the aryl hydrocarbon receptor. Environ Sci Pollut Res Int 20: 8045–8056. 10.1007/s11356-013-1628-7.23539207
Louisse, J; Dellafiora, L; van den Heuvel, JJM, W; Rijkers, D; Leenders, L; Dome, JCM; Punt, A; Russel, FGM; Koenderink, JB. (2022). Perfluoroalkyl substances (PFASs) are substrates of the renal human organic anion transporter 4 (OAT4). Arch Toxicol 97: 685–696. 10.1007/s00204-022-03428-6.36436016
Luo, D; Wu, WX; Pan, YA; Du, BB; Shen, MJ; Zeng, LX. (2021). Associations of prenatal exposure to per- and polyfluoroalkyl substances with the neonatal birth size and hormones in the growth hormone/insulin-like growth factor axis. Environ Sci Technol 55:11859–11873. 10.1021/acs.est.1c02670.34378915
Luo, F; Chen, Q; Yu, G; Huo, X; Wang, H; Nian, M; Tian, Y; Xu, J; Zhang, J; Zhang, J. (2022a). Exposure to perfluoroalkyl substances and neurodevelopment in 2-year-old children: A prospective cohort study. Environ Int 166: 107384. 10.1016/i.envint.2022.107384.35834943
Luo, K; Huang, W; Zhang, Q; Liu, X; Nian, M; Wei, M; Wang, Y; Chen, D; Chen, X; Zhang, J. (2022b). Environmental exposure to legacy poly/perfluoroalkyl substances, emerging alternatives and isomers and semen quality in men: A mixture analysis. Sci Total Environ 833: 155158. 10.1016/i.scitotenv.2022.155158.35421474
Luo, K; Liu, X; Zhou, W; Nian, M; Qiu, W; Yang, Y; Zhang, J. (2022c). Preconception exposure to perfluoroalkyl and polyfluoroalkyl substances and couple fecundity: A couple-based exploration. Environ Int 170:107567. 10.1016/i.envint.2022.107567.36240624
Luo, M; Tan, Z; Dai, M; Song, D; Lin, J; Xie, M; Yang, J; Sun, L; Wei, D; Zhao, J; Gonzalez, FJ; Liu, A. (2017). Dual action of peroxisome proliferator-activated receptor alpha in perfluorodecanoic acid-induced hepatotoxicity. Arch Toxicol 91: 897–907. 10.1007/s00204-016-1779-7.27344344
Luster, MI; Johnson, VJ; Yucesoy, B; Simeonova, PP. (2005). Biomarkers to assess potential developmental immunotoxicity in children. Toxicol Appl Pharmacol 206: 229–236. 10.1016/j.taap.2005.02.010.15967213
Ma, K; Saha, PK; Chan, L; Moore, DD. (2006). Farnesoid X receptor is essential for normal glucose homeostasis. J Clin Invest 116:1102–1109. 10.1172/JCI25604.16557297
Ma, X; Cui, L; Chen, L; Zhang, J; Zhang, X; Kang, Q; Jin, F; Ye, Y. (2021). Parental plasma concentrations of perfluoroalkyl substances and In Vitro fertilization outcomes. Environ Pollut 269: 116159. 10.1016/i.envpol.2020.116159.33279270
Ma, Y; Sachdeva, K; Liu, J; Song, X; Li, Y; Yang, D; Deng, R; Chichester, CO; Yan, B. (2005). Clofibrate and perfluorodecanoate both upregulate the expression of the pregnane X receptor but oppositely affect its ligand-dependent induction on cytochrome P450 3A23. Biochem Pharmacol 69: 1363–1371. 10.1016/j.bcp.2005.02.011.15826607
Mackowiak, B; Hodge, J; Stern, S; Wang, H. (2018). The roles of xenobiotic receptors: Beyond chemical disposition [Review], Drug Metab Dispos 46:1361–1371. 10.1124/dmd.118.081042.29759961
Maher, JM; Aleksunes, LM; Dieter, MZ; Tanaka, Y; Peters, JM; Manautou, JE; Klaassen, CD. (2008). Nrf2- and PPAR alpha-mediated regulation of hepatic Mrp transporters after exposure to perfluorooctanoic acid and perfluorodecanoic acid. Toxicol Sci 106: 319–328. 10.1093/toxsci/kfn177.18757529
Malhi, H; Gores, GJ. (2008). Cellular and molecular mechanisms of liver injury [Review]. Gastroenterology 134: 1641–1654. 10.1053/i.gastro.2008.03.002.18471544
Mamsen, LS; Björvang, RD; Mucs, D; Vinnars, MT; Papadogiannakis, N; Lindh, CH; Andersen, CY; Damdimopoulou, P. (2019). Concentrations of perfluoroalkyl substances (PFASs) in human embryonic and fetal organs from first, second, and third trimester pregnancies. Environ Int 124: 482–492. 10.1016/i.envint.2019.01.010.30684806
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Iniguez, C; Martinez, D; Costa, O; Santa-Marina, L; Pereda-Pereda, E; Schettgen, T; Sunyer, J; Vrijheid, M. (2017). Prenatal exposure to perfluoroalkyl substances and birth outcomes in a Spanish birth cohort. Environ Int 108: 278–284. 10.1016/j.envint.2017.09.006.28917208
Maranhao Neto, GA; Polcrova, AB; Pospisilova, A; Blaha, L; Klanova, J; Bobak, M; GonzalezRivas, JP. (2022). Associations between Per- and Polyfluoroalkyl Substances (PFAS) and Cardiometabolic Biomarkers in Adults of Czechia: The Kardiovize Study. Int J Environ Res Public Health 19: 13898. 10.3390/ijerph192113898.36360776
Meek, ME; Boobis, A; Cote, I; Dellarco, V; Fotakis, G; Munn, S; Seed, J; Vickers, C. (2014). New developments in the evolution and application of the WHO/IPCS framework on mode of action/species concordance analysis [Review]. J Appl Toxicol 34:1–18. 10.1002/jat.2949.24166207
Mehta, SS; James-Todd, T; Applebaum, KM; Bellavia, A; Coleman-Phox, K; Adler, N; Laraia, B; Epel, E; Parry, E; Wang, M; Park, JS; Zota, AR. (2021). Persistent organic pollutants and maternal glycemic outcomes in a diverse pregnancy cohort of overweight women. Environ Res 193: 110551. 10.1016/j.envres.2020.110551.33278474
Mellor, CL; Steinmetz, FP; Cronin, MT. (2016). The identification of nuclear receptors associated with hepatic steatosis to develop and extend adverse outcome pathways [Review]. Crit Rev Toxicol 46:138–152. 10.3109/10408444.2015.1089471.26451809
Meng, Q; Inoue, K; Ritz, B; Olsen, J; Liew, Z. (2018). Prenatal exposure to perfluoroalkyl substances and birth outcomes; An updated analysis from the Danish national birth cohort. Int J Environ Res Public Health 15:1832. 10.3390/ijerph15091832.30149566
Morken, NH; Travlos, GS; Wilson, RE; Eggesbø, M; Longnecker, MP. (2014). Maternal glomerular filtration rate in pregnancy and fetal size. PLoS ONE 9: e101897. 10.1371/journal.pone.0101897.25003331
Nian, M; Luo, K; Luo, F; Aimuzi, R; Huo, X; Chen, Q; Tian, Y; Zhang, J. (2020). Association between prenatal exposure to PFAS and fetal sex hormones: Are the short-chain PFAS safer? Environ Sci Technol 54: 8291–8299. 10.1021/acs.est.0c02444.32525661
NTP (National Toxicology Program). (2016). NTP Monograph: Immunotoxicity associated with exposure to perfluorooctanoic acid (PFOA) or perfluorooctane sulfonate (PFOS). Research Triangle Park, NC: U.S. Department of Health and Human Services, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pfoa_pfos/pfoa_pfosmonograph_508.pdf.
NTP (National Toxicology Program). (2018). 28-day evaluation of the toxicity (C20615) of perfluorodecanoic acid (PFDA) (335–76-2) on Harlan Sprague-Dawley rats exposed via gavage [NTP]. U.S. Department of Health and Human Services. 10.22427/NTP-DATA-002-02652-0004-0000-1.
Oguro, T; Hayashi, M; Nakajo, S; Numazawa, S; Yoshida, T. (1998). The expression of heme oxygenase-l gene responded to oxidative stress produced by phorone, a glutathione depletor, in the rat liver; the relevance to activation of c-jun n-terminal kinase. J Pharmacol Exp Ther 287: 773–778.9808709
Oh, J; Bennett, DH; Tancredi, DJ; Calafat, AM; Schmidt, RJ; Hertz-Picciotto, 1; Shin, HM. (2022a). Longitudinal Changes in Maternal Serum Concentrations of Per- and Polyfluoroalkyl Substances from Pregnancy to Two Years Postpartum. Environ Sci Technol 56:11449–11459. 10.1021/acs.est.1c07970.35904360
Oh, J; Shin, HM; Kannan, K; Busgang, SA; Schmidt, RJ; Schweitzer, JB; Hertz-Picciotto, I; Bennett, DH. (2022b). Childhood exposure to per- and polyfluoroalkyl substances and neurodevelopment in the CHARGE case-control study. Environ Res 215:114322. 10.1016/i.envres.2022.114322.36108719
Oh, S; Son, M; Byun, KA; Jang, JT, .; Choi, CH, .; Son, KH, .; Byun, K. (2021). Attenuating effects of dieckol on high-fat diet-induced nonalcoholic fatty liver disease by decreasing the nlrp3 inflammasome and pyroptosis. Drugs 19: 318. 10.3390/md19060318.
Ohmori, K; Kudo, N; Katayama, K; Kawashima, Y. (2003). Comparison of the toxicokinetics between perfluorocarboxylic acids with different carbon chain length. Toxicology 184: 135–140. 10.1016/S0300-483X(02)00573-5.12499116
Ojo, AF; Peng, C; Ng, JC. (2020). Combined effects and toxicological interactions of perfluoroalkyl and polyfluoroalkyl substances mixtures in human liver cells (HepG2). Environ Pollut 263: 114182. 10.1016/i.envpol.2020.114182.32247900
Ojo, AF; Peng, C; Ng, JC. (2022). Genotoxicity assessment of per- and polyfluoroalkyl substances mixtures in human liver cells (HepG2). Toxicology 482:153359. 10.1016/j.tox.2022.153359.36341878
Ojo, AF; Xia, Q; Peng, C; Ng, JC. (2021). Evaluation of the individual and combined toxicity of perfluoroalkyl substances to human liver cells using biomarkers of oxidative stress. Chemosphere 281:130808. 10.1016/j.chemosphere.2021.130808.34022600
Olson, CT; Andersen, ME. (1983). The acute toxicity of perfluorooctanoic and perfluorodecanoic acids in male rats and effects on tissue fatty acids. Toxicol Appl Pharmacol 70: 362–372. 10.1016/0041-008x(83)90154-0.6636169
Ouidir, M; Buck Louis, GM; Kanner, J; Grantz, KL; Zhang, C; Sundaram, R; Rahman, ML; Lee, S; Kannan, K; Tekola-Ayele, F; Mendola, P. (2020). Association of maternal exposure to persistent organic pollutants in early pregnancy with fetal growth. JAMA Pediatr 174: 149–161. 10.1001/iamapediatrics.2019.5104.31886849
Oulhote, Y; Coull, B; Bind, MA; Debes, F; Nielsen, F; Tamayo, I; Weihe, P; Grandjean, P. (2019). Joint and independent neurotoxic effects of early life exposures to a chemical mixture: A multi-pollutant approach combining ensemble learning and g-computation. Environmental Epidemiology 3: e063. 10.1097/ee9.0000000000000063.32051926
Padula, AM; Ning, X; Bakre, S; Barrett, ES; Bastain, T; Bennett, DH; Bloom, MS; Breton, CV; Dunlop, AL; Eick, SM; Ferrara, A; Fleisch, A; Geiger, S; Goin, DE; Kannan, K; Karagas, MR; Korrick, S; Meeker, JD; Morello-Frosch, R. (2023). Birth outcomes in relation to prenatal exposure to per-and polyfluoroalkyl substances and stress in the environmental influences on child health outcomes (echo) program [Supplemental Data]. Environ Health Perspect 131: (037006) 037001–037011. 10.1289/EHP10723.36856429
Pan, Y; Cui, Q; Wang, J; Sheng, N; Jing, J; Yao, B; Dai, J. (2019). Profiles of emerging and legacy per-/polyfluoroalkyl substances in matched serum and semen samples: New implications for human semen quality. Environ Health Perspect 127:127005. 10.1289/EHP4431.31841032
Pan, Y; Zhu, Y; Zheng, T; Cui, Q; Buka, SL; Zhang, B; Guo, Y; Xia, W; Yeung, LW; Li, Y; Zhou, A; Qiu, L; Liu, H; Jiang, M; Wu, C; Xu, S; Dai, J. (2017). Novel Chlorinated Polyfluorinated Ether Sulfonates and Legacy Per-/Polyfluoroalkyl Substances: Placental Transfer and Relationship with Serum Albumin and Glomerular Filtration Rate. Environ Sci Technol 51: 634–644. 10.1021/acs.est.6b04590.27931097
Passen, EL; Andersen, BR. (1986). Clinical tetanus despite a protective level of toxin-neutralizing antibody [Case Report]. JAMA 255:1171–1173. 10.1001/iama.1986.03370090093029.2868135
Patel, JC; Mehta, BC. (1999). Tetanus: Study of 8, 697 cases. Indian J Med Sci 53: 393–401.10710833
Perez, F; Nadal, M; Navarro-Ortega, A; Fabrega, F; Domingo, JL; Barcelo, D; Farre, M. (2013). Accumulation of perfluoroalkyl substances in human tissues. Environ Int 59: 354–362. 10.1016/j.envint.2013.06.004.23892228
Permadi, H; Lundgren, B; Andersson, K; Sundberg, C; Depierre, JW. (1993). Effects of perfluoro fatty acids on peroxisome proliferation and mitochondrial size in mouse liver: dose and time factors and effect of chain length. Xenobiotica 23: 761–770. 10.3109/004982593Q9166782.8237058
Peterson, AK; Eckel, SP; Habre, R; Yang, T; Faham, D; Amin, M; Grubbs, BH; Farzan, SF; Kannan, K; Robinson, M; Lerner, D; Al-Marayati, LA; Walker, DK; Grant, EG; Breton, CV; Bastain, TM. (2022). Detected prenatal perfluorooctanoic acid (PFOA) exposure is associated with decreased fetal head biometric parameters in participants experiencing higher perceived stress during pregnancy in the MADRES cohort. 9. 10.1016/j.envadv.2022.100286.
Petroff, RL; Cavalcante, RG; Langen, ES; Dolinov, DC; Padmanabhan, V; Goodrich, JM. (2023). Mediation effects of DNA methylation and hydroxymethylation on birth outcomes after prenatal per- and polyfluoroalkyl substances (PFAS) exposure in the Michigan motherinfant Pairs cohort. Clinical Epigenetics 15: 49. 10.1186/s13148-02301461-5.36964604
Pirard, C; Dufour, P; Charlier, C. (2020). Background contamination of perfluoralkyl substances in a Belgian general population. Toxicol Lett 333:13–21. 10.1016/j.toxlet.2020.07.015.32659468
Powers, RH; Aust, SD. (1986). The effects of nonadecafluoro-n-decanoic acid on serum retinol and hepatic retinyl palmitate hydrolase activity in male Sprague-Dawley rats. J Biochem Toxicol 1: 27–42. 10.1002/jbt.2570010204.3271875
Qu, J; Zhao, Y; Zhang, L; Hu, S; Liao, K; Zhao, M; Wu, P; Jin, H. (2022). Evaluated serum perfluoroalkyl acids and their relationships with the incidence of rheumatoid arthritis in the general population in Hangzhou, China. Environ Pollut 307:119505. 10.1016/i.envpol.2022.119505.35605832
Rangel, PL; RodrÍguez, A; Gutierrez, CG. (2007). Testosterone directly induces progesterone production and interacts with physiological concentrations of LH to increase granulosa cell progesterone production in laying hens (Gallus domesticus). Anim Reprod Sci 102: 56–65. 10.1016/j.anireprosci.2006.09.029.17081706
Rantakokko, P; Mnnist, V; Airaksinen, R; Koponen, J; Viluksela, M; Kiviranta, H; Pihlajamäki, J. (2015). Persistent organic pollutants and non-alcoholic fatty liver disease in morbidly obese patients: A cohort study. Environ Health 14: 79. 10.1186/s12940-015-0066-z.26420011
Reo, NV; Adinehzadeh, M. (2000). NMR spectroscopic analyses of liver phosphatidylcholine and phosphatidylethanolamine biosynthesis in rats exposed to peroxisome proliferators-A class of nongenotoxic hepatocarcinogens. Toxicol Appl Pharmacol 164:113–126. 10.1006/taap.2000.8901.10764624
Reo, NV; Goecke, CM; Narayanan, L; Jarnot, BM. (1994). Effects of perfluoro-n-octanoic acid, perfluoro-n-decanoic acid, and clofibrate on hepatic phosphorus metabolism in rats and guinea pigs in vivo. Toxicol Appl Pharmacol 124:165–173. 10.1006/taap.1994.1020.8122261
Reves, L; Manalich, R. (2005). Long-term consequences of low birth weight [Review]. Kidney Int Suppl 68: S107–S111. 10.1111/j.1523-1755.2005.09718.x.
Rivera-Nunez, Z; Kinkade, CW; Khoury, L; Brunner, J; Murphy, H; Wang, C; Kannan, K; Miller, RK; O'Connor, TG; Barrett, ES. (2023). Prenatal perfluoroalkyl substances exposure and maternal sex steroid hormones across pregnancy. Environ Res 220:115233. 10.1016/j.envres.2023.115233.36621543
Robledo, CA; Yeung, E; Mendola, P; Sundaram, R; Maisog, J; Sweeney, AM; Barr, DB; Louis, GM. (2015). Preconception maternal and paternal exposure to persistent organic pollutants and birth size: the LIFE study. Environ Health Perspect 123: 88–94. 10.1289/ehp.1308016.25095280
Rosen, EM; Brantsæter, AL; Carroll, R; Haug, L; Singer, AB; Zhao, S; Ferguson, KK. (2018). Maternal Plasma Concentrations of Per- and polyfluoroalkyl Substances and Breastfeeding Duration in the Norwegian Mother and Child Cohort. Environmental Epidemiology 2: e027. 10.1097/EE9.0000000000000027.30298140
Rosen, MB; Das, KP; Wood, CR; Wolf, CJ; Abbott, BD; Lau, C. (2013). Evaluation of perfluoroalkyl acid activity using primary mouse and human hepatocytes. Toxicology 308:129–137. 10.1016/j.tox.2013.03.011.23567314
Rosenmai, AK; Ahrens, L; Ie Godec, T; Lundqvist, J; Oskarsson, A. (2018). Relationship between peroxisome proliferator-activated receptor alpha activity and cellular concentration of 14 perfluoroalkyl substances in HepG2 cells. J Appl Toxicol 38: 219–226. 10.1002/jat.3515.28857218
Roth, RA; Jaeschke, H; Luyendyk, JP. (2019). Chapter 13: Toxic responses of the liver. In CD Klaassen (Ed.), Casarett & Doull's toxicology: The basic science of poisons (9th ed., pp. 719–766). New York, NY: McGraw Hill.
Routti, H; Berg, MK; Lille-Langøy, R; Øygarden, L; Harju, M; Dietz, R; Sonne, C; Goksøyr, A. (2019). Environmental contaminants modulate the transcriptional activity of polar bear (Ursus maritimus) and human peroxisome proliferator-activated receptor alpha (PPARα). Sci Rep 9: 6918. 10.1038/s41598-019-43337-w.31061404
Ru, HY; Davis, JA. (2024). Dose-response modeling files for the PFDA IRIS Assessment: U.S. Environmental Protection Agency; U.S. Department of Health and Human Services.
Running, L; Atilla-Gokcumen, GE; Aga, DS. (2022). Development of a liquid chromatographymass spectrometry-based in vitro assay to assess changes in steroid hormones due to exposure to per- and polyfluoroalkyl substances. Chern Res Toxicol 35:1277–1288. 10.1021/acs.chemrestox.2c00116.
Russell, DW. (2003). The enzymes, regulation, and genetics of bile acid synthesis [Review]. Annu Rev Biochem 72: 137–174. 10.1146/annurev.biochem.72.121801.161712.12543708
Sagiv, SK; Rifas-Shiman, SL; Fleisch, AF; Webster, TF; Calafat, AM; Ye, X; Gillman, MW; Oken, E. (2018). Early Pregnancy Perfluoroalkyl Substance Plasma Concentrations and Birth Outcomes in Project Viva: Confounded by Pregnancy Hemodynamics? Am J Epidemiol 187: 793–802. 10.1093/aje/kwx332.29155920
Salihović, S; Dickens, AM; Schoultz, I; Fart, F; Sinisalu, L; Lindeman, T; Halfvarson, J; Oresic, M; Hyötyläinen, T. (2019). Simultaneous determination of perfluoroalkyl substances and bile acids in human serum using ultra-high-performance liquid chromatography-tandem mass spectrometry. Anal Bioanal Chern 412: 2251–2259. 10.1007/s00216-019-02263-6.
Salo, HM; Koponen, J; Kiviranta, H; Rantakokko, P; Honkanen, J; Harkonen, T; Ilonen, J; Virtanen, SM; Tillmann, V; Knip, M; Vaarala, O; Knip, M; Koski, K; Koski, M; Harkonen, T; Ryhanen, S; Hamalainen, A; Ormisson, A; Peet, A; Tillmann, V; Ulich, V; Kuzmicheva, E; Mokurov, S; Markova, S; Pylova, S; Isakova, M; Shakurova, E; Petrov, V; Dorshakova, NV; Karapetyan, T; Varlamova, T; Ilonen, J; Kiviniemi, M; Alnek, K; Janson, H; Uibo, R; Salum, T; von Mutius, E; Weber, J; Ahlfors, H; Kallionpaa, H; Laajala, E; Lahesmaa, R; Lahdesmaki, H; Molder, R; Nieminen, J; Ruohtula, T; Vaarala, O; Honkanen, H; Hyoty, H; Kondrashova, A; Oikarinen, S; Harmsen, HJM; De Goffau, MC; Welling, G; Alahuhta, K; Virtanen, SM; Grp, DS. (2019). No evidence of the role of early chemical exposure in the development of -cell autoimmunity. Environ Sci Pollut Res Int 26:1370–1378. 10.1007/s11356-018-3659-6.30426368
Salvatier, J; Wiecki, TV; Fonnesbeck, C. (2016). Probabilistic programming in Python using PyMC3. PeerJ Computer Science 2: e55. 10.7717/peerj-cs.55.
Sanghavi, M; Rutherford, JD. (2014). Cardiovascular physiology of pregnancy. Circulation 130: 1003–1008. 10.1161/CIRCULATIONAHA.114.009029.25223771
Schillemans, T; Iszatt, N; Remy, S; Schoeters, G; Fernandez, MF; D'Cruz, SC; Desalegn, A; Haug, LS; Lignell, S; Lindroos, AK; Fábelová, L; Murinova, LP; Kosjek, T; Tkalec, Ž; Gabriel, C; Sarigiannis, D; Pedraza-Díaz, S; Esteban-López, M; Castaño, A; … Åkesson, A. (2022). Cross-sectional associations between exposure to per- and polyfluoroalkyl substances and body mass index among European teenagers in the HBM4EU aligned studies. Environ Pollut 316: 120566. 10.1016/j.envpol.2022.120566.36334774
Schlosser, P. (2024). Model code for the classical pharmacokinetic modeling and alternate dosimetric analyses of PFDA in support of the IRIS Toxicological Review [Computer Program].
Schramm, H; Friedberg, T; Robertson, LW; Oesch, F; Kissel, W. (1989). Perfluorodecanoic acid decreases the enzyme activity and the amount of glutathione S-transferases proteins and mRNAs in vivo. Chern Biol Interact 70: 127–143. 10.1016/00092797(89)90068-9.
Selgrade, MK. (2007). Immunotoxicity: The risk is real [Review]. Toxicol Sci 100: 328–332. 10.1093/toxsci/kfm244.17878151
Shearer, JJ; Callahan, CL; Calafat, AM; Huang, WY; Jones, RR; Sabbisetti, VS; Freedman, ND; Sampson, JN; Silverman, DT; Purdue, MP; Hofmann, JN. (2021). Serum concentrations of per- and polyfluoroalkyl substances and risk of renal cell carcinoma. J Natl Cancer Inst 113: 580–587. 10.1093/inci/djaa143.32944748
Shiue, I. (2015a). Arsenic, heavy metals, phthalates, pesticides, hydrocarbons and polyfluorinated compounds but not parabens or phenols are associated with adult remembering condition: US NHANES, 2011–2012. Environ Sci Pollut Res Int 22: 6381–6386. 10.1007/s11356-015-4261-9.25744817
Shiue, I. (2015b). Urinary heavy metals, phthalates and polyaromatic hydrocarbons independent of health events are associated with adult depression: USA NHANES, 20112012. Environ Sci Pollut Res Int 22: 17095–17103. 10.1007/s11356015-4944-2.26126689
Shiue, I. (2015c). Urinary heavy metals, phthalates, perchlorate, nitrate, thiocyanate, hydrocarbons, and polyfluorinated compounds are associated with adult hearing disturbance: USA NHANES, 2011–2012. Environ Sci Pollut Res Int 22: 20306–20311. 10.1007/s11356-015-5546-8.26490897
Shiue, I. (2015d). Urinary heavy metals, phthalates, phenols, thiocyanate, parabens, pesticides, polyaromatic hydrocarbons but not arsenic or polyfluorinated compounds are associated with adult oral health: USA NHANES. 2011–2012. Environ Sci Pollut Res Int 22: 15636–15645. 10.1007/s11356-015-4749-3.26018285
Sood, S; Ojo, AO; Adu, D; Kannan, K; Ghassabian, A; Koshy, T; Vento, SM; Pehrson, U; Gilbert, JF; Arogundade, FA; Ademola, AD; Salako, BO; Raji, Y; Osafo, C; Antwi, S; Trachtman, H; Trasande, L; Ajayi, S; Burke, D; Cooper, R; Gbadegesin, R; Ilori, T; Mamven, M; Olanrewaju, T; Parekh, R; Rhule, J; Salako, T; Tayo, B; Ulasi, I; Investigators, HAKDRN. (2019). Association Between Perfluoroalkyl Substance Exposure and Renal Function in Children With CKD Enrolled in H3Africa Kidney Disease Research Network. 4: 1641–1645. 10.1016/j.ekir.2019.07.017.
Sovadinova, I; Babica, P; Böke, H; Kumar, E; Wilke, A; Park, JS; Trosko, JE; Upham, BL. (2015). Phosphatidylcholine Specific PLC-Induced Dysregulation of Gap Junctions, a Robust Cellular Response to Environmental Toxicants, and Prevention by Resveratrol in a Rat Liver Cell Model. PLoS ONE 10: e0124454. 10.1371/journal.pone.0124454.26023933
Stalling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Ye, X; Dabelea, D. (2017). Perfluoroalkyl substances during pregnancy and offspring weight and adiposity at birth: Examining mediation by maternal fasting glucose in the healthy start study. Environ Health Perspect 125: 067016. 10.1289/EHP641.28669937
Starling, AP; Liu, C; Shen, G; Yang, IV; Kechris, K; Borengasser, SJ; Boyle, KE; Zhang, W; Smith, HA; Calafat, AM; Hamman, RF; Adgate, JL; Dabelea, D. (2020). Prenatal Exposure to Perand Polyfluoroalkyl Substances, Umbilical Cord Blood DNA Methylation, and CardioMetabolic Indicators in Newborns: The Healthy Start Study. Environ Health Perspect 128: 127014. 10.1289/EHP6888.33356526
Steenland, K; Barry, V; Savitz, D. (2018). Serum perfluorooctanoic acid and birthweight: an updated meta-analysis with bias analysis. Epidemiology 29: 765–776. 10.1097/EDE.0000000000000903.30063543
Sterchele, PF; Sun, H; Peterson, RE; Vanden Heuvel, JP. (1996). Regulation of peroxisome proliferator-activated receptor-alpha mRNA in rat liver. Arch Biochem Biophys 326: 281–289. 10.1006/abbi.1996.0077.8611035
Sterchele, PF; Vanden Heuvel, JP; Davis, JW; Shrago, E; Knudsen, J; Peterson, RE. (1994). Induction of hepatic acyl-CoA-binding protein and liver fatty acid-binding protein by perfluorodecanoic acid in rats. Lack of correlation with hepatic long-chain acyl-CoA levels. Biochem Pharmacol 48: 955–966. 10.1016/00062952(94)90366-2.8093108
Sun, X; Xie, Y; Zhang, X; Song, J; Wu, Y. (2023). Estimation of per- and polyfluorinated alkyl substance induction equivalency factors for humpback dolphins by transactivation potencies of peroxisome proliferator-activated receptors. Environ Sci Technol 57: 3713–3721. 10.1021/acs.est.2c05044.36812292
Swedish Environmental Protection Agency. (2017). [Rapport till Naturvårdsverkets halsorelaterade miljbbvervakning: Utvardering av samband mellan mammors POPbelastning under graviditets-och amningsperioden och deras barns hälsa]. (2215–17008).
Taibi, KR; Liang, D; Dunlop, AL; Barr, DB; Smith, MR; Steenland, K; Tan, Y; Ryan, PB; Panuwet, P; Everson, T; Marsit, CJ; Kannan, K; Jones, DP; Eick, SM. (2023). Pregnancy-related hemodynamic biomarkers in relation to trimester-specific maternal per - and polyfluoroalkyl substances exposures and adverse birth outcomes. Environ Pollut 323: 121331. 10.1016/j.envpol.2023.121331.36813097
Takacs, ML; Abbott, BD. (2007). Activation of mouse and human peroxisome proliferatoractivated receptors (alpha, beta/delta, gamma) by perfluorooctanoic acid and perfluorooctane sulfonate. Toxicol Sci 95:108–117. 10.1093/toxsci/kfl135.17047030
Takagi, A; Sai, K; Umemura, T; Hasegawa, R; Kurokawa, Y. (1991). Short-term exposure to the peroxisome proliferators, perfluorooctanoic acid and perfluorodecanoic acid, causes significant increase of 8-hydroxydeoxyguanosine in liver DNA of rats. Cancer Lett 57: 55–60. 10.1016/0304-3835(91)90063-N.2025879
Takahashi, S; Tanaka, N; Golla, S; Fukami, T; Krausz, KW; Polunas, MA; Weig, BC; Masuo, Y; Xie, C; Jiang, C; Gonzalez, FJ. (2017). Editor's highlight: farnesoid X receptor protects against low-dose carbon tetrachloride-induced liver injury through the taurocholateJNKpathway. Toxicol Sci 158: 334–346. 10.1093/toxsci/kfx094.28505368
Tan, Y; Zeng, Z; Liang, H; Weng, X; Yao, H; Fu, Y; Li, Y; Chen, J; Wei, X; Jing, C. (2022). Association between Perfluoroalkyl and Polyfluoroalkyl Substances and Women's Infertility, NHANES 2013–2016. Int J Environ Res Public Health 19. 10.3390/ijerph192215348.
Tian, M, .; Reichetzeder, C, .; Li, J, .; Hocher, B, . (2019). Low birth weight, a risk factor for diseases in later life, is a surrogate of insulin resistance at birth. J Hypertens 37: 2123–2134. 10.1097/HJH.0000000000002156.31157747
Tian, Y; Luan, M; Zhang, J; Yang, H; Wang, Y; Chen, H. (2022). Associations of single and multiple perfluoroalkyl substances exposure with folate among adolescents in NHANES 20072010. Chemosphere 307: 135995. 10.1016/j.chemosphere.2022.135995.35981617
Tillaut, H; Monfort, C; Giton, F; Warembourg, C; Rouget, F; Cordier, S; Laine, F; Gaudreau, E; Garlantezec, R; Saint-Amour, D; Chevrier, C. (2022). Persistent organic pollutant exposure and thyroid function among 12-year-old children. Neuroendocrinology. 10.1159/000528631.
Timmermann, CA; Budtz-Jørgensen, E; Petersen, MS; Weihe, P; Steuerwald, U; Nielsen, F; Jensen, TK; Grandjean, P. (2017). Shorter duration of breastfeeding at elevated exposures to perfluoroalkyl substances. Reprod Toxicol 68:164–170. 10.1016/j.reprotox.2016.07.010.27421579
Traba, J; Kwarteng-Siaw, M; Okoli, TC; Li, J; Huffstutler, RD; Bray, A; Waclawiw, MA; Han, K; Pelletier, M; Sauve, AA; Siegel, RM; Sack, MN. (2015). Fasting and refeeding differentially regulate NLRP3 inflammasome activation in human subjects. 125: 4592–4600. 10.1172/JCI83260.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report], (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOK EN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment [EPA Report]. (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30004YQB.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report], (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council, https://www.epa.gov/scientific-leadership/peer-review-handbook-4th-edition-2015.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16–002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division, https://www.epa.gov/sites/production/files/201605/documents/pfos_hesd_final_508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16–003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division, https://www.epa.gov/sites/production/files/2016-05/documents/pfoa_hesd_final-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2018). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 335-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 335-49-3) (public comment draft). (EPA-823-R-18307). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2019). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 335-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 335-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Systematic review protocol for the PFAS IRIS assessments. (EPA/635/R-19/050). https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). CompTox Chemicals Dashboard [Bioactivity] [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2022b). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). Review of EPA's analyses to support EPA's national primary drinking water rulemaking for PFAS. (EPA-SAB-22–008). https://sab.epa.gov/ords/sab/f?p=100:18:16490947993:::18:P18_ID:2601.
U.S. EPA (U.S. Environmental Protection Agency). (2023a). Charge question clarification support document for draft IRIS PFDA assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2023b). IRIS toxicological review of perfluorohexanoic acid [PFHxA, CASRN 335-24-4] and related salts [EPA Report]. (EPA/635/R-23/027Fa). Washington, D.C.: U.S. Environmental Protection Agency:: U.S. EPA. https://iris.epa.gov/ChemicalLanding/&substance_nmbr=704.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). Final Human health toxicity assessment for perfluorooctane sulfonic acid (PFOS) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Final human health toxicity assessment for perfluorooctanoic acid (PFOA) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
Valvi, D; Oulhote, Y; Weihe, P; Dalgård, C; Bjerve, KS; Steuerwald, U; Grandjean, P. (2017). Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107: 205–215. 10.1016/j.envint.2017.07.016.28753482
Van Anders, SM; Watson, NV. (2006). Menstrual cycle irregularities are associated with testosterone levels in healthy premenopausal women. Am J Hum Biol 18: 841–844. 10.1002/ajhb.20555.17039468
van Otterdijk, FM. (2007). Repeated dose 90-day oral toxicity study with MTDID 8391 by daily gavage in the rat followed by a 3-week recovery period. (Study Number 06–398). Maplewood, MN: 3M.
Van Rafelghem, MJ; Andersen, ME. (1988). The effects of perfluorodecanoic acid on hepatic stearoyl-coenzyme A desaturase and mixed function oxidase activities in rats. Fundam Appl Toxicol 11: 503–510. 10.1016/0272-0590(88)90114-5.2906022
Van Rafelghem, MJ; Mattie, DR; Bruner, RH; Andersen, ME. (1987). Pathological and hepatic ultrastructural effects of a single dose of perfluoro-n-decanoic acid in the rat, hamster, mouse, and guinea pig. Fundam Appl Toxicol 9: 522–540. 10.1016/0272-0590(87)90034-0.3692011
Van Rafelghem, MJ; Vanden Heuvel, JP; Menahan, LA; Peterson, RE. (1988). Perfluorodecanoic acid and lipid metabolism in the rat. Lipids 23: 671–678. 10.1007/BF02535666.3419281
Vanden Heuvel, JP; Kuslikis, Bl; Shrago, E; Peterson, RE. (1991). Inhibition of long-chain acyl-CoA synthetase by the peroxisome proliferator perfluorodecanoic acid in rat hepatocytes. Biochem Pharmacol 42: 295–302. 10.1016/0006-2952(91)90716-1.1859447
Vanden Heuvel, JP; Sterchele, PF; Nesbit, DJ; Peterson, RE. (1993). Coordinate induction of acylCoA binding protein, fatty acid binding protein and peroxisomal beta-oxidation by peroxisome proliferators. Biochim Biophys Acta 1177:183–190. 10.1016/0167-4889(93)90039-R.8499488
Wahlang, B; Beier, JI; Clair, HB; Bellis-Jones, HJ; Falkner, K; Mcclain, CJ; Cave, MC. (2013). Toxicant-associated steatohepatitis [Review]. Toxicol Pathol 41: 343–360. 10.1177/0192623312468517.23262638
Wallace, KB; Kissling, GE; Melnick, RL; Blystone, CR. (2013). Structure-activity relationships for perfluoroalkane-induced in vitro interference with rat liver mitochondrial respiration. Toxicol Lett 222: 257–264. 10.1016/j.toxlet.2013.07.025.23954199
Wang, B; Chen, Q; Shen, L; Zhao, S; Pang, W; Zhang, J. (2016). Perfluoroalkyl and polyfluoroalkyl substances in cord blood of newborns in Shanghai, China: Implications for risk assessment [Review]. Environ Int 97: 7–14. 10.1016/i.envint.2016.10.008.27770709
Wang, D; Gao, Q; Wang, T; Kan, Z; Li, X; Hu, L; Peng, CY; Qian, F; Wang, Y; Granato, D. (2020). Green tea polyphenols and epigallocatechin-3-gallate protect against perfluorodecanoic acid induced liver damage and inflammation in mice by inhibiting NLRP3 inflammasome activation. Food Res Int 127: 108628. 10.1016/i.foodres.2019.108628.31882076
Wang, H; Li, W; Yang, J; Wang, Y; Du, H; Han, M; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2023). Gestational exposure to perfluoroalkyl substances is associated with placental DNA methylation and birth size. Sci Total Environ 858: 159747. 10.1016/j.scitotenv.2022.159747.36309289
Wang, J; Pan, Y; Cui, Q; Yao, B; Wang, J; Dai, J. (2018). Penetration of PFASs across the blood cerebrospinal fluid barrier and its determinants in humans. Environ Sci Technol 52: 13553–13561. 10.1021/acs.est.8b04550.30362723
Wang, T; Xu, H; Guo, Y; Li, Z; Ye, H; Wu, L; Guo, Y; Wang, D. (2022). Perfluorodecanoic acid promotes adipogenesis via NLRP3 inflammasome-mediated pathway in HepG2 and 3T3L1 cells. Food Chern Toxicol 171: 113520. 10.1016/j.fct.2022.113520.
Wang, W; Zhou, W; Wu, S; Liang, F; Li, Y; Zhang, J; Cui, L; Feng, Y; Wang, Y. (2019). Perfluoroalkyl substances exposure and risk of polycystic ovarian syndrome related infertility in Chinese women. Environ Pollut 247: 824–831. 10.1016/j.envpol.2019.01.039.30731307
Wang, YM; Chai, SC; Brewer, CT; Chen, T. (2014). Pregnane X receptor and drug-induced liver injury [Review]. Expert Opin Drug Metab Toxicol 10: 1521–1532. 10.1517/17425255.2014.963555.25252616
Watt, ED; Judson, RS. (2018). Uncertainty quantification in ToxCast high throughput screening. PLoS ONE 13: e0196963. 10.1371/journal.pone.0196963.30044784
Weisskopf, MG; Seals, RM; Webster, TF. (2018). Bias amplification in epidemiologic analysis of exposure to mixtures. Environ Health Perspect 126. 10.1289/EHP2450.
Weisskopf, MG; Webster, TF. (2017). Trade-offs of personal versus more proxy exposure measures in environmental epidemiology. Epidemiology 28: 635–643. 10.1097/EDE.0000000000000686.28520644
Whitworth, KW; Haug, LS; Baird, DD; Becher, G; Hoppin, JA; Skjaerven, R; Thomsen, C; Eggesbo, M; Travlos, G; Wilson, R; Longnecker, MP. (2012). Perfluorinated compounds and subfecundity in pregnant women. Epidemiology 23: 257–263. 10.1097/EDE.0b013e31823b5Q31.22081060
Whitworth, KW; Haug, LS; Sabaredzovic, A; Eggesbo, M; Longnecker, MP. (2016). Brief Report: Plasma Concentrations of Perfluorooctane Sulfonamide and Time-to-pregnancy Among Primiparous Women. Epidemiology 27: 712–715. 10.1097/EDE.0000000000000524.27276029
Wielsøe, M; Eiberg, H; Ghisari, M; Kern, P; Lind, O; Bonefeld-Jørgensen, EC. (2018). Genetic variations, exposure to persistent organic pollutants and breast cancer risk - a greenlandic case-control study. Basic & Clinical Pharmacology & Toxicology Online Pharmacology Online 123: 335–346. 10.1111/bcpt.13002.
Wielspe, M; Kern, P; Bonefeld-Jørgensen, EC. (2017). Serum levels of environmental pollutants is a risk factor for breast cancer in Inuit: a case control study. Environ Health 16: 56. 10.1186/s12940-017-0269-6.28610584
Wielsøe, M; Long, M; Ghisari, M; Bonefeld-Jørgensen, EC. (2015). Perfluoroalkylated substances (PFAS) affect oxidative stress biomarkers in vitro. Chemosphere 129: 239–245. 10.1016/j.chemosphere.2014.10.014.25455676
Wikström, S; Lin, PI; Lindh, CH; Shu, H; Bornehag, CG. (2020). Maternal serum levels of perfluoroalkyl substances in early pregnancy and offspring birth weight. Pediatr Res 87: 1093–1099. 10.1038/s41390-019-0720-1.31835271
Witzmann, F; Coughtrie, M; Fultz, C; Lipscomb, J. (1996). Effect of structurally diverse peroxisome proliferators on rat hepatic sulfotransferase. Chern Biol Interact 99: 73–84. 10.1016/0009-2797(95)03661-X.
Witzmann, FA; Parker, DN. (1991). Hepatic protein pattern alterations following perfluorodecanoic acid exposure in rats. Toxicol Lett 57: 29–36. 10.1016/0378-4274(91)90116-N.2048159
Wolf, CJ; Schmid, JE; Lau, C; Abbott, BD. (2012). Activation of mouse and human peroxisome proliferator-activated receptor-alpha (PPARα) by perfluoroalkyl acids (PFAAs): further investigation of C4-C12 compounds. Reprod Toxicol 33: 546–551. 10.1016/j.reprotox.2011.09.009.22107727
Wolf, CJ; Takacs, ML; Schmid, JE; Lau, C; Abbott, BD. (2008). Activation of mouse and human peroxisome proliferator-activated receptor alpha by perfluoroalkyl acids of different functional groups and chain lengths. Toxicol Sci 106:162–171. 10.1093/toxsci/kfn166.18713766
Woods, MM; Lanphear, BP; Braun, JM; McCandless, LC. (2017). Gestational exposure to endocrine disrupting chemicals in relation to infant birth weight: A Bayesian analysis of the HOME Study. Environ Health 16:115. 10.1186/s12940-017-0332-3.29078782
Workman, CE; Becker, AB; Azad, MB; Moraes, TJ; Mandhane, PJ; Turvey, SE; Subbarao, P; Brook, JR; Sears, MR; Wong, CS. (2019). Associations between concentrations of perfluoroalkyl substances in human plasma and maternal, infant, and home characteristics in Winnipeg, Canada. Environ Pollut 249: 758–766. 10.1016/j.envpol.2019.03.054.30933773
Wright, JM; Larsen, A; Rappazzo, K; Ru, H; Radke, EG; Bateson, TF. (2023). Systematic review and meta-analysis of birthweight and PFNA exposures [Review]. Environ Res 222: 115357. 10.1016/j.envres.2023.115357.36706898
Xu, C; Zhang, L; Zhou, Q; Ding, J; Yin, S; Shang, X; Tian, Y. (2022). Exposure to per- and polyfluoroalkyl substances as a risk factor for gestational diabetes mellitus through interference with glucose homeostasis. Sci Total Environ 838:156561. 10.1016/i.scitotenv.2022.156561.35691348
Xu, H; Zhou, Q; Zhang, J; Chen, X; Zhao, H; Lu, H; Ma, B; Wang, Z; Wu, C; Ying, C; Xiong, Y; Zhou, Z; Li, X. (2020). Exposure to elevated per- and polyfluoroalkyl substances in early pregnancy is related to increased risk of gestational diabetes mellitus: A nested casecontrol study in Shanghai, China. Environ Int 143:105952. 10.1016/j.envint.2020.105952.32717645
Xu, K; Guidez, F; Glasow, A; Chung, D; Petrie, K; Stegmaier, K; Wang, KK; Zhang, J; Jing, Y; Zelent, A; Waxman, S. (2005). Benzodithiophenes potentiate differentiation of acute promyelocytic leukemia cells by lowering the threshold for ligand-mediated corepressor/coactivator exchange with retinoic acid receptor alpha and enhancing changes in all-trans-retinoic acid-regulated gene expression. Cancer Res 65: 7856–7865. 10.1158/0008-5472.CAN-05-1056.16140955
Yamamoto, A; Kawashima, Y. (1997). Perfluorodecanoic acid enhances the formation of oleic acid in rat liver. Biochem J 325 ( Pt 2): 429–434. 10.1042/bj3250429.9230124
Yang, L; Ji, H; Liang, H; Yuan, W; Song, X; Li, X; Niu, J; Shi, H; Wen, S; Miao, M. (2022a). Associations of perfluoroalkyl and polyfluoroalkyl substances with gestational hypertension and blood pressure during pregnancy: A cohort study. Environ Res 215: 114284. 10.1016/j.envres.2022.114284.36088993
Yang, X; Schnakenberg, LK; Shi, Q; Salminen, WF. (2014). Hepatic toxicity biomarkers. In RC Gupta (Ed.), Biomarkers in Toxicology (pp. 241–259). New York, NY: Academic Press. 10.1016/B978-0-12-404630-6.00013-0.
Yang, Z; Men, K; Guo, J; Liu, R; Liu, H; Wei, J; Zhang, J; Liu, L; Lin, X; Zhang, M; Liu, Y; Chen, Y; Tang, NJ. (2022b). Association between exposure to perfluoroalkyl substances and uric acid in Chinese adults. Chemosphere 312:137164. 10.1016/j.chemosphere.2022.137164.36351467
Yao, J; Dong, Z; Jiang, L; Pan, Y; Zhao, M; Bai, X; Dai, J. (2023). Emerging and Legacy Perfluoroalkyl Substances in Breastfed Chinese Infants: Renal Clearance, Body Burden, and Implications. Environ Health Perspect 131: 37003-37003. 10.1289/EHP11403.36862174
Yao, J; Pan, Y; Sheng, N; Su, Z; Guo, Y; Wang, J; Dai, J. (2020). Novel perfluoroalkyl ether carboxylic acids (PFECAs) and sulfonic acids (PFESAs): Occurrence and association with serum biochemical parameters in residents living near a fluorochemical plant in China. Environ Sci Technol 54:13389–13398. 10.1021/acs.est.0c02888.33047597
Yao, Q; Gao, Y; Zhang, Y; Qin, K; Liew, Z; Tian, Y. (2021). Associations of paternal and maternal per- and polyfluoroalkyl substances exposure with cord serum reproductive hormones, placental steroidogenic enzyme and birth weight. Chemosphere 285:131521. 10.1016/j.chemosphere.2021.131521.34273704
Ye, WL; Chen, ZX; Xie, YQ; Kong, ML; Li, QQ; Yu, S; Chu, C; Dong, GH; Zeng, XW. (2021). Associations between serum isomers of perfluoroalkyl acids and metabolic syndrome in adults: Isomers of C8 Health Project in China. Environ Res 196:110430. 10.1016/j.envres.2020.110430.33181135
Yu, Y; Qin, XD; Bloom, MS; Chu, C; Dai, X; Li, QQ; Chen, ZX; Kong, ML; Xie, YQ; Meng, WJ; Yang, BY; Hu, LW; Zeng, XW; Zhao, XM; Zhou, Y; Dong, GH. (2022). Associations of prenatal exposure to perfluoroalkyl substances with preterm birth: A family-based birth cohort study. Environ Res 214: 113803. 10.1016/i.envres.2022.113803.35810818
Zeng, X; Chen, T; Cui, Y; Zhao, J; Chen, Q; Yu, Z; Zhang, Y; Han, L; Chen, Y; Zhang, J. (2023). In utero exposure to perfluoroalkyl substances and early childhood BMI trajectories: A mediation analysis with neonatal metabolic profiles. Sci Total Environ 867:161504. 10.1016/i.scitotenv.2023.161504.36634772
Zhang, L; Ren, XM; Guo, LH. (2013). Structure-based investigation on the interaction of perfluorinated compounds with human liver fatty acid binding protein. Environ Sci Technol 47: 11293–11301. 10.1021/es4026722.24006842
Zhang, LY; Ren, XM; Wan, B; Guo, LH. (2014). Structure-dependent binding and activation of perfluorinated compounds on human peroxisome proliferator-activated receptor γ. Toxicol Appl Pharmacol 279: 275–283. 10.1016/j.taap.2014.06.020.24998974
Zhang, M; Yu, CH; Wang, G; Buckley, JP; Hong, X; Pearson, C; Adams, WG; Fan, ZT; Wang, X. (2022). Longitudinal trajectories and determinants of plasma per- and polyfluoroalkyl substance (PFAS) levels from birth to early childhood and metabolomic associations: A pilot study in the Boston Birth Cohort. 1.
Zhang, Y; Chen, R; Gao, Y; Qu, J; Wang, Z; Zhao, M; Bai, X; Jin, H. (2023). Human serum poly- and perfluoroalkyl substance concentrations and their associations with gestational diabetes mellitus. Environ Pollut 317: 120833. 10.1016/j.envpol.2022.120833.36493933
Zhang, YM; Dong, XY; Fan, LJ; Zhang, ZL; Wang, Q; Jiang, N; Yang, XS. (2017). Poly- and perfluorinated compounds activate human pregnane X receptor. Toxicology 380: 23–29. 10.1016/j.tox.2017.01.012.28115241
Zhao, C; Wang, S; Zhai, Y; Wang, M; Tang, Y; Li, H; Im, YJ; Ge, RS. (2023). Direct inhibition of human and rat 11β-hydroxysteroid dehydrogenase 2 by per- and polyfluoroalkyl substances: Structure-activity relationship and in silico docking analysis. Toxicology 488: 153484. 10.1016/j.tox.2023.153484.36878351
Zhao, W; Cui, R; Wang, J; Dai, J. (2017). Inhibition effects of perfluoroalkyl acids on progesterone production in mLTC-1. J Environ Sci 56: 272–280. 10.1016/i.jes.2016.08.026.
Zhao, X; Lin, JY; Dong, WW; Tang, ML; Yan, SG. (2022). Per- and polyfluoroalkyl substances exposure and bone mineral density in the U.S. population from NHANES 2005–2014. J Expo Sci Environ Epidemiol. 10.1038/s41370-022-00452-7.
Zhou, T; Ross, DG; Devito, MJ; Crofton, KM. (2001). Effects of short-term in vivo exposure to polybrominated diphenyl ethers on thyroid hormones and hepatic enzyme activities in weanling rats. Toxicol Sci 61: 76–82. 10.1093/toxsci/61.1.76.11294977
Zhou, Y; Li, Q; Wang, P; Li, J; Zhao, W; Zhang, L; Wang, H; Cheng, Y; Shi, H; Li, J; Zhang, Y. (2023). Associations of prenatal PFAS exposure and early childhood neurodevelopment: Evidence from the Shanghai Maternal-Child Pairs Cohort. Environ Int 173:107850. 10.1016/j.envint.2023.107850.36857906
Zota, AR; Geller, RJ; Romano, LE; Coleman-Phox, K; Adler, NE; Parry, E; Wang, M; Park, JS; Elmi, AF; Laraia, BA; Epel, ES. (2018). Association between persistent endocrine-disrupting chemicals (PBDEs, OH-PBDEs, PCBs, and PFASs) and biomarkers of inflammation and cellular aging during pregnancy and postpartum. Environ Int 115: 9–20. 10.1016/j.envint.2018.02.044.29533840