# APPENDIX I EPA CHARACTERIZATION OF STUDIES IDENTIFIED AFTER PUBLIC RELEASE OF THE IRIS TOXICOLOGICAL REVIEW OF PERFLUORODECANOIC ACID (PFDA) AND RELATED SALTS

Tables I-1, I-2 and I-3 below describe literature identified during the 2023 literature search update performed after release of the public comment draft (as described in Section 1.2.1 of the IRIS perfluorodecanoic acid external review draft) or submitted in public comments received through the EPA docket^9^ or during external peer review. In accordance with charge question 1, the tables show EPA's disposition on the need to incorporate these studies into the finalized Toxicological Review and the interpreted impact of these studies on key judgments in the draft Toxicological Review (i.e., identified hazards and dose-response values, or pivotal uncertainties). The panel is asked to weigh in on EPA's disposition. Supplemental study categories included here are “ADME" and “mechanistic, including non-PECO exposure route.” All identified studies not meeting PECO or the aforementioned supplemental categories can be found in the HERO (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614) database.

Table I-1 Human studies meeting assessment PECO criteria

Reference | Source^a^ | Health outcome | Results summary | EPA disposition on incorporation and characterization of impact^b^
Immune effects
Kaur et al. (2023) | Lit update | Antibody levels to SARS-COV2 in adults | Inverse but not statistically significant association (beta −0.15, 95% CI: −0.60, 0.29) | No.; Findings are consistent with existing evidence and have no impact on immunosuppression conclusions (which are primarily based on studies in children) and on initial review; there are concerns for risk of bias due to lack of consideration of other COVID risk factors).
Gaylord et al. (2019) | Commenter | Asthma | No association with asthma diagnosis (OR 0.90, 95% CI: 0.69, 1.17) | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Averina et al. (2019) | Commenter | Asthma | No association with asthma, eczema, allergies | No.; Existing evidence on asthma is inconsistent and new studies do not change current draft judgment.
Ammitzbøll et al. (2019) | Commenter | Multiple sclerosis | No association with multiple sclerosis overall, but an indication of interaction by sex (positive association in women, inverse association in men) | No.; The evidence on potential associations with autoimmune is sparse and would likely be indeterminate for autoimmune effects overall.
Qu et al. (2022) | Lit update | Rheumatoid arthritis | No association with rheumatoid arthritis | No.; The evidence on potential associations with autoimmune is sparse and would likely be indeterminate for autoimmune effects overall.
Gaylord et al. (2020) | Commenter | Celiac disease | No association with celiac disease (OR 0.89, 95% CI: 0.55, 1.46) | No.; The evidence on potential associations with autoimmune is sparse and would likely be indeterminate for autoimmune effects overall.
Developmental effects
Hall et al. (2022) | Lit Update | Fetal growth restriction/Gestational duration | Inverse associations for PFDA and both BWT and gestational age in males only. Associations were large (~ −200 g) for BWT and statistically significant for gestational age (~ −1.5 wk). | No.; The inverse associations in males along with null results in females would not change the current draft judgment for fetal growth restriction or gestational duration.
Wang et al. (2023) | Lit update | Fetal growth restriction (birth length (BL); head circumference (HC); birthweight (BWT)) | BL Male β = −0.061 (95% CI: −0.102, 0.223). Female β = −0.175 (95% CI: −0.470, 0.120).; HC Male β = −0.036 (95% CI: −0.247, 0.174). Female β = −0.311 (95% CI: −0.528, −0.093).; BWT Male β = 0.010 (95% CI: −0.176, 0.197). Female β = −0.010 (95% CI: −0.176, 0.197). | No.; The inverse associations (BL and HC) in females along with null BWT results in females and null results in males for all three endpoints would not change the current draft judgment for fetal growth restriction.
Peterson et al. (2022) | Lit update | Fetal growth restriction | Small nonsignificant head circumference results and null associations for fetal biparietal diameter (Figure 2). | No.; Mixed results for fetal biometric endpoints would not change the current draft judgment for fetal growth restriction.
Padula et al. (2023) | Lit update | Fetal growth restriction, preterm birth | GA β = −0.11 (95% CI: −0.32, 0.09) BWT_GA β = −0. 25 (95% CI: −0.37, −0.14) Term LBW OR = 2.24 (95% CI: 0.96, 5.24) SGA OR = 1.18 (95% CI: 0.81, 1.73) LGA OR = 0.52 (95% CI: 0.35, 0.77) PTB OR = 1.22 (95% CI: 0.80, 1.86) | No.; Null results for PTB, SGA and increased and inverse risks for Term LBW and GA and BWT-GA would not change the current draft judgment for either gestational duration or fetal growth restriction.
Ouidir et al. (2020) | Commenter | Fetal growth restriction | Positive associations with some fetal growth measures based on ultrasonography. | No.; Study population was previously reported in a publication already in the Toxicological Review, Buck Louis et al. (2018). New results for in utero measurements would not change the current draft judgment.
Petroff et al. (2023) | Lit update | Gestational age | GA β = −0.27 ± 0.17 (p = 0.114). | No.; Small nonsignificant inverse association with gestational age would not change the current draft judgment for gestational duration.
Yu et al. (2022) | Lit update | Preterm birth | OR = 1.20 (95% CI: 0.95, 1.53) per ln-unit increase OR = 1.52 (95% CI: 0.96, 2.42) per ng/mL increase | No.; Small increased risks here along with the null results in Padula et al. (2023) and Liao et al. (2022b) would not change the current draft judgment for gestational duration.
Liao et al. (2022b) | Lit update | Preterm birth | PTB per unit increase (OR = 0.985; 95% CI: 0.624, 1.556) and tertiles (T3 OR = 1.066; 95% CI: 0.677, 1.679; T2 OR = 0.815; 95% CI: 0.511, 1.302). | No.; The null results here and for Padula et al. (2023) above combined with small increased risks by Yu et al. (2022) above would not change the current draft judgment for gestational duration.
Wang et al. (2016) | Commenter | Preterm birth | Similar PFDA concentrations in term and preterm births | No.; This study reported only mean exposure concentrations without control for confounding so would not influence existing judgment.
Hong et al. (2022) | Lit update | Spontaneous abortion | Inverse but not statistically significant associations (OR 0.23, 95% CI: 0.03, 1.70 for IVF group, OR = 0.67; 95% CI: 0.16, 2.73 for entire clinic population | No.; Updated analysis of study that is already included in the draft Toxicological Review.
Li et al. (2022a) | Lit update | Anogenital distance | No association.; AGD-AF: β = 0.29 (95% CI: −0.12, 0.70) AGD-AC: β = 0.35 (95% CI: −0.16, 0.85) AGI-AF: β = 0.07 (95% CI: −0.06, 0.19) AGI-AC: β = 0.07 (95% CI: −0.12, 0.26) | No.; Null findings would not change the current draft judgment.
Hepatic
Rantakokko et al. (2015) | Commenter | Nonalcoholic fatty liver disease | Inverse association with lobular inflammation (OR 0.05, 95% CI: <0.01, 0.83 for 2–4 foci per 200× field) | Yes.; Based on peer-review comments, there was some disagreement about whether the human evidence for hepatic effects was slight as presented in the draft or moderate. The new studies were added to determine whether they provided support to move to change the judgment.
Borghese et al. (2022) | Lit update | Liver enzymes | Positive but not statistically significant associations with AST and GGT, no association with ALP (ALT not analyzed with PFDA for unspecified reason)
Liao et al. (2023) | Lit update | Liver enzymes | No association with ALT, AST, GGT, bilirubin
Kim et al. (2023b) | Lit update | Liver enzymes | Positive but not statistically significant associations with ALT, AST, and GGT
Yao et al. (2020) | Commenter | Liver enzymes | Positive association with ALT, AST, GGT (statistically significant for GGT)
Salihović et al. (2019) | Commenter | Bile acid levels (liver) | Association of PFDA and bile acids examined in human plasma | No.; Results would not change draft judgments.
Cancer
Feng et al. (2022a) | Lit update | Breast cancer | No association with breast cancer (OR = 0.98, 95% CI: 0.77, 1.25) per unit increase in ln-transformed plasma PFDA levels | No.; Inconsistent results across the new studies and the only other study reported nonsignificantly increased risk of breast cancer among women ≤50 yr of age; and nonsignificantly decreased risk of breast cancer among women >50 yr of age. In addition, one new breast cancer study reports on the same study population as a publication already in the Toxicological Review, Wielsøe et al. (2017). For liver cancer, the two studies are inconsistent. The weak association observed for renal cancer dissipated when controlled for other PFAS. The available epidemiological evidence on PFDA and the risk of cancer remains inadequate; the new studies are not impactful.
Li et al. (2022d) | Lit update | Breast cancer | Increased risk for breast cancer (OR = 2.22, 95% CI: 1.55, 3.17) per SD increase in ln-transformed PFDA.
Wielsøe et al. (2018) | Commenter | Breast cancer | Positive but not statistically significant association (OR 2.66, 95% CI: 0.64, 11.1 in high vs. low exposure for one genotype)
Lee et al. (2020) | Commenter | Breast cancer | No association with mammographic density (beta −0.21, p-value = 0.5)
Goodrich et al. (2022) | Lit update | Liver cancer | No association with liver cancer (OR = 0.8, 95% CI: 0.31, 2.00) for PFDA greater than the 90th% vs. less than 90th%.
Cao et al. (2022) | External peer reviewer | Liver cancer | Positive but not statistically significant association with liver cancer (OR 1.18, 95% CI: 0.96, 1.40 per log-unit increase in PFDA)
Shearer et al. (2021) | Commenter | Renal cancer | Positive but not statistically significant association with renal cell carcinoma (OR 1.70, 95% CI: 0.72, 4.03 in Q4 vs. Q1)
Neurodevelopment
Luo et al. (2022a) | Lit update | Broad neurodevelopmental scale | Inverse association with cognitive, language, and motor scores, but not social-emotional or adaptive behavior scores | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Oh et al. (2022b) | Lit update | Autism, developmental delay | No increase in odds of autism spectrum disorder, developmental delay | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Zhou et al. (2023) | Lit update | Broad neurodevelopmental scale | Inverse association with communication, motor, problem solving, and personal-social (latter two not statistically significant) at 6 mo but not other visits (2,12, and 24 mo) | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Li et al. (2023c) | Lit update | Broad neurodevelopmental scale | Positive association with persistently low trajectory for gross motor (p < 0.05), problem solving ability, and personal-social skills, but not communication, fine motor | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Oulhote et al. (2019) | Commenter | Broad neurodevelopmental scale | No association with total scores to Boston Naming Test or Strengths and Difficulties Questionnaire | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Kim et al. (2023a) | Lit update | ADHD scale | Positive though nonmonotonic association with ADHD rating scale at 8 yr, dependent on age at exposure measurement | No.; There is considerable inconsistency in the evidence for neurodevelopmental effects, and the new studies would not influence the draft synthesis judgment of slight evidence.
Male reproductive
Luo et al. (2022b) | Lit update | Semen parameters | Inverse but not statistically significant association with motility | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Pan et al. (2019) | Commenter | Semen parameters | Direction of association for motility differed when exposure measured in semen vs. serum (both nonsignificant); no association with concentration or morphology; statistically significant association with increased DNA fragmentation and seminal PFDA levels | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Ma et al. (2021) | Commenter | Semen parameters | Inverse but not statistically significant association with sperm concentration and morphology; no association with motility | No.; Evidence is inconsistent and the new studies would not influence the draft conclusion.
Rivera-Núñez et al. (2023) | Lit update | Reproductive hormones | Positive association with free T but not T, E1, E2, or E3 | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Nian et al. (2020) | Commenter | Reproductive hormones | No association with total testosterone (beta −0.029, 95% CI: −0.09, 0.032 per ln-unit change), FSH, or LH | No.; Evidence is inconsistent in existing studies and the new studies would not influence the draft synthesis conclusion of indeterminate evidence.
Female reproductive
Hong et al. (2022) | Lit update | In vitro fertilization outcomes | No association with oocyte maturation rate, fertilization rate, high quality embryo rate; inverse but not statistically significant association (OR = 0.81, 95% CI: 0.46–1.41) for clinical pregnancy | No.; Evidence of an association with fecundity and infertility is inconsistent across new studies and was similarly inconsistent across existing studies.; The conclusion of indeterminate evidence would remain the same; the new studies are not impactful to draft conclusions.
Cohen et al. (2023) | Lit update | Fecundity, pregnancy | Longer time to pregnancy (FR 0.90, 95% CI: 0.82, 0.98) and lower odds of clinical pregnancy (OR 0.74, 95% CI: 0.56, 0.98)
Luo et al. (2022c) | Lit update | Fecundity, infertility | No association with reduced fecundability (FR 1.06, 95% CI: 0.92,1.20) or infertility (OR 0.96, 95% CI: 0.74, 1.26)
Tan et al. (2022) | Lit update | Infertility | Lower odds of infertility (nonmonotonic across quartiles and not statistically significant)
Buck Louis et al. (2013) | Commenter | Fecundity | No association with reduced fecundability (FR 1.11, 95% CI: 0.95, 1.29)
Whitworth et al. (2016) | Commenter | Fecundity | No association (FR 1.00, 95% CI: 0.85, 1.2)
Ma et al. (2021) | Commenter | In vitro fertilization outcomes, pregnancy | No association with number of oocytes, zygotes, embryos, or clinical pregnancies
Wang et al. (2019) | Commenter | Polycystic ovarian syndrome | Positive but not statistically significant association with PCOS-related infertility (OR 2.06, 95% CI: 0.63, 6.78 in 3rd vs. 1st tertile) | No.; Existing evidence on gynecological conditions is inconsistent and new study does not change conclusions.
Rivera-Núñez et al. (2023) | Lit update | Reproductive hormones | Inverse association with E1 (p < 0.05) and T, positive association with FT (p < 0.05); no association with E2, E3 | No.; New studies would not change the current draft judgment.
Nian et al. (2020) | Commenter | Reproductive hormones | No association with total testosterone (beta −0.029, 95% CI: −0.09, 0.032 per ln-unit change), FSH, or LH | No.; New studies would not change the current draft judgment.
Liu et al. (2020a) | Commenter | Reproductive hormones | Positive association with estradiol (9.1% change, 95% CI: 4.6, 13.8) | No.; New studies would not change the current draft judgment.
Lin et al. (2022) | Lit update | Postpartum hemorrhage | Higher odds of postpartum hemorrhage (OR 1.16, 95% CI: 0.48, 2.82) but imprecise | No.; Single study of the outcome and evidence is not strong enough to increase certainty in the evidence for female reproductive effects.
Rosen et al. (2018) | Commenter | Breastfeeding duration | Lower hazard of breastfeeding cessation with higher exposure | Yes. New section added to the Toxicological Review based on peer-review feedback.
Timmermann et al. (2017) | Commenter | Breastfeeding duration | Inverse association with duration of breastfeeding | Yes. New section added to the Toxicological Review based on peer-review feedback.
Pirard et al. (2020) | Commenter | Breastfeeding duration | No association with breastfeeding duration | No. Analyses designed to predict PFNA concentrations based on past breastfeeding duration without prospective measurement of exposure; high likelihood of reverse causation.
Ammitzbøll et al. (2019) | Commenter | Breastfeeding duration | Inverse association with breastfeeding duration in crude analysis | No. Analyses designed to predict PFNA concentrations based on past breastfeeding duration without prospective measurement of exposure; high likelihood of reverse causation.
Harris et al. (2017) | Commenter | Breastfeeding duration | Inverse association with breastfeeding duration in crude analysis | No. Analyses designed to predict PFNA concentrations based on past breastfeeding duration without prospective measurement of exposure; high likelihood of reverse causation.
Kim et al. (2020) | Commenter | Breastfeeding duration | Inverse association with breastfeeding duration in crude analysis | No. Analyses designed to predict PFNA concentrations based on past breastfeeding duration without prospective measurement of exposure; high likelihood of reverse causation.
Lee et al. (2018) | Commenter | Breastfeeding duration | Moderate positive correlation with breastfeeding duration in crude analysis | No. Analyses designed to predict PFNA concentrations based on past breastfeeding duration without prospective measurement of exposure; high likelihood of reverse causation.
Urinary
Liang et al. (2023) | Lit update | Glomerular filtration rate | Positive association with GFR in women | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Sood et al. (2019) | Commenter | Glomerular filtration rate | Inverse association with eGFR (beta −18.3, 95% CI: −35.3, −1.3) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Feng et al. (2022b) | Lit update | Hyperuricemia | No association with hyperuricemia | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Yang et al. (2022b) | Lit update | Hyperuricemia | No association with hyperuricemia | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Arrebola et al. (2019) | Commenter | Hyperuricemia | No association with hyperuricemia | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Yao et al. (2020) | Commenter | Uric acid | Positive association with uric acid (beta 5.13, 95% CI: 1.92, 8.33) | No.; Existing studies are inconsistent with considerable uncertainty due to potential reverse causation. The new studies do not inform this uncertainty.
Cardiometabolic
Maranhao Neto et al. (2022) | Lit update | Serum lipids, blood pressure, adiposity, blood glucose | Inverse associations with blood glucose, adiposity, and total cholesterol; no association with blood pressure | No.; Mixed results from the new studies would not change the current draft judgment.
Haug et al. (2023) | Lit update | Serum lipids | Positive association with HDL and LDL cholesterol | No.; Mixed results from the new studies would not change the current draft judgment.
Donat-Vargas et al. (2019b) | Commenter | Serum lipids, hypertension | No association with total cholesterol, triglycerides, or hypertension | No.; Mixed results from the new studies would not change the current draft judgment.
Yao et al. (2020) | Commenter | Serum lipids, blood glucose | Positive association with total cholesterol (beta 6.29, 95% CI: 3.25, 9.53) and triglycerides, no association with blood glucose | No.; Mixed results from the new studies would not change the current draft judgment.
Sood et al. (2019) | Commenter | Blood pressure | No association with blood pressure (beta 0.4, 95% CI: −0.2, 0.9) | No.; Mixed results from the new studies would not change the current draft judgment.
Lind et al. (2018) | Commenter | Carotid artery intima-media thickness | Positive association with IMT thickness (beta 0.02, 95% CI: 0.006, 0.033) | No.; These results support coherence with serum lipids but would not change the current draft judgment.
Li et al. (2023b) | Lit update | Cardiovascular disease | No association with acute coronary syndrome | No.; New study contributes to existing inconsistency and would not change the current draft judgment.
Yang et al. (2022a) | Lit update | Gestational hypertension | Lower odds of gestational hypertension (OR 0.68, 95% CI: 0.47, 0.97) and lower continuous blood pressure | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Huo et al. (2020) | Lit update | Gestational hypertension | No association with gestational hypertension (OR 0.96, 9f% CI 0.63, 1.46) or preeclampsia (OR 0.95, 95% CI: 0.64, 1.41) | No.; New studies contribute to existing inconsistency and would not change the current draft judgment.
Xu et al. (2022) | Lit update | Gestational diabetes | No clear association with gestational diabetes (positive but not statistically significant odds ratio in third tertile but inverse in second tertile), no association with continuous blood glucose in oral glucose tolerance test | No.; Existing studies are primarily null and new studies with imprecise results and no clear dose-dependence would not change the current draft judgment.
Zhang et al. (2023) | Lit update | Gestational diabetes | No clear association with gestational diabetes (positive but not statistically significant odds ratio in third tertile but inverse in second tertile) | No.; Existing studies are primarily null and new studies with imprecise results and no clear dose-dependence would not change the current draft judgment.
Xu et al. (2020) | Lit update | Gestational diabetes | No association with gestational diabetes (OR 0.76, 95% CI: 0.23, 1.91 per log-unit) | No.; Existing studies are primarily null and new studies with imprecise results and no clear dose-dependence would not change the current draft judgment.
Li et al. (2020) | Commenter | Gestational blood glucose | Positive but not statistically significant association with blood glucose in oral glucose tolerance test (beta 0.10, 95% CI: −0.05, 0.25) | No.; Existing studies are primarily null and new studies with imprecise results and no clear dose-dependence would not change the current draft judgment.
Dunder et al. (2023) | Lit update | Diabetes, blood glucose | Inverse but small and not statistically significant association (−0.01, 95% CI: −0.03, 0.006), stronger in women than men | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Christensen et al. (2016) | Commenter | Diabetes | Positive association with prediabetes (OR 2.72, 95% CI: 1.28, 6.13) but not diabetes (OR 1.00, 95% CI: 0.32,2.19) | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Duan et al. (2021) | External peer reviewer | Diabetes | Inverse association with type 2 diabetes (OR 0.46, 95% CI: 0.25, 0.82 in T3 vs. T1) | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Donat-Vargas et al. (2019a) | Commenter | Diabetes risk, insulin resistance | No increase in diabetes risk or HOMA-IR | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Kim et al. (2015) | Commenter | Insulin resistance | Positive but not statistically significant association with HOMA (beta 0.32, 95% CI: −0.28, 0.93) | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Mehta et al. (2021) | Commenter | Insulin resistance | No association with blood glucose or HOMA-IR | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Brosset and Ngueta (2022) | Lit update | Glycemic control | No association with poor glycemic control | No.; Existing studies are primarily null and mixed results in new studies would not change the current draft judgment.
Ye et al. (2021) | Commenter | Metabolic syndrome | Positive association with metabolic syndrome (OR 1.29, 95% CI: 0.96, 1.72) fasting blood glucose, triglycerides, and waist circumference | No. Studies are inconsistent and new study would not change the current draft judgment.
Schillemans et al. (2022) | Lit update | Adiposity | No association with BMI z-score | No.; Mixed results in new studies would not change the current draft judgment.
Zeng et al. (2023) | Lit update | Adiposity | Positive association (p < 0.05) with persistent increase for BMI z-score trajectory | No.; Mixed results in new studies would not change the current draft judgment.
Harris et al. (2017) | Commenter | Adiposity | Lower PFDA levels in obese and overweight participants (−15.6% difference, 95% CI: −28.7, −0.1 for obese vs. normal) | No.; Mixed results in new studies would not change the current draft judgment.
Ji et al. (2012) | Commenter | Adiposity | Mean PFDA levels highest in normal weight participants (no statistical analysis) | No.; Mixed results in new studies would not change the current draft judgment.
Pirard et al. (2020) | Commenter | Adiposity | Inverse association (beta −0.022, p-value 0.003) with PFDA concentration modeled as outcome | No.; Mixed results in new studies would not change the current draft judgment.
Liu et al. (2020b) | Commenter | Adiposity | Inverse association with BMI (beta −0.01) | No.; Mixed results in new studies would not change the current draft judgment.
Endocrine
Jensen et al. (2022) | Lit update | Thyroid hormones | No association with free T4 or TSH | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Derakhshan et al. (2022) | Lit update | Thyroid hormones | Positive association with free T4 (beta 0.27, 95% CI: 0.10, 0.45) but no association with TSH or free T3 | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Li et al. (2023a) | Lit update | Thyroid hormones | Inverse but not statistically significant association with TSH in TPOAb participants, no association with free T4 | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Tillaut et al. (2022) | Lit update | Thyroid hormones | Inverse association with free T3 (p < 0.05) and TSH (p > 0.05), no association with free T4 | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Jain and Ducatman (2019) | Commenter | Thyroid hormones | No association with T4, T3, or TSH | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Dufour et al. (2020) | Commenter | Thyroid disease | Inverse association with hypothyroidism (OR 0.19, 95% CI: 0.05, 0.81) and hyperthyroidism (OR 0.17, 95% CI: 0.05, 0.57) | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Christensen et al. (2016) | Commenter | Thyroid disease | Inverse association with thyroid disease (OR 0.17, 95% CI: 0.01, 1.12) | No.; Existing studies are primarily null and new studies would not change the current draft judgment.
Other
Højsager et al. (2022) | Lit update | Bone mineral density | Inverse association with bone mineral content and density (p < 0.05) | No.; Available studies are inconsistent, and evidence would likely be indeterminate.
Zhao et al. (2022) | Lit update | Bone mineral density | No association with femur bone mineral density | No.; Available studies are inconsistent, and evidence would likely be indeterminate.
Colicino et al. (2020) | Lit update | Bone mineral density | No association with lumbar spine or femur density | No.; Available studies are inconsistent, and evidence would likely be indeterminate.
Shiue (2015d) | Commenter | Oral health | No association with teeth health, tooth ache, tooth loss | No.; Available studies are inconsistent, and evidence would likely be indeterminate.
Liao et al. (2022a) | Lit update | Hematology | Positive but nonmonotonic and not statistically significant association with gestational anemia (low hemoglobin) in the first and third but not second trimesters; no association with hemoglobin concentration during pregnancy | No.; Inconsistent results in studies of hemoglobin. Evidence would likely be indeterminate overall.
Cui et al. (2022) | Lit update | Hematology | Positive association with hematocrit (2.70% change, 95% CI: 1.33, 4.1) and hemoglobin (2.50% change, 95% CI: 1.03, 3.99) during pregnancy | No.; Inconsistent results in studies of hemoglobin. Evidence would likely be indeterminate overall.
Liu et al. (2022) | Lit update | Hematology | Inverse association with white blood cells and neutrophils | No.; Inconsistent results in studies of hemoglobin. Evidence would likely be indeterminate overall.
Shiue (2015a) | Commenter | Neurologic; remembering condition | No association with difficulty remembering (RR 1.01, 95% CI: 0.54–1.90 for >3× per wk) | No.; Lack of association in available studies and would likely be indeterminate overall.
Shiue (2015b) | Commenter | Neurologic; depression | No association with adult depression | No.; Lack of association in available studies and would likely be indeterminate overall.
Shiue (2015c) | Commenter | Neurologic; hearing disturbance | No association with trouble hearing | No.; Lack of association in available studies and would likely be indeterminate overall.
Gaylord et al. (2019) | Commenter | Pulmonary function | No association with FEV or FVC (FEV1 beta −0.03, 95% CI: −0.09, 0.03, FVC beta −0.03, 95% CI: −0.10, 0.04) | No.; Lack of association in available study and would likely be indeterminate overall.

ADHD: Attention deficit hyperactive syndrome; AGD: anogenital distance; AGI: anogenital index; ALP: alkaline phosphatase; ALT: alanine aminotransferase; AST: aminotransferase; BL: birth length; BMI: body mass index; BWT: birth weight;E1:estrone; E2:estradiol; E3: estriol; eGFR: estimated glomerular filtration; FEV: forced expiratory volume; FSH: follicle-stimulating hormone; FVC: forced vital capacity; GFR: glomerular filtration rate; HDL: high density lipoprotein; HOMA-IR: homeostatic model assessment of insulin resistance; LBW: low birth weight; LDL: low density lipoprotein; LGA: Large for gestational age: LH: luteinizing hormone; PCOS: polycystic ovary syndrome; PTB: preterm birth; T: testosterone; T3: triiodothyronine; T4: thyroxine; TPOAb: thyroid peroxidase antibody; TSH: thyroid stimulating hormone.

a For literature identified by public commenters, the full comments are available here: https://www.regulations.gov/docket/EPA-HQ-ORD-2019-0287.

b As described in charge question 1, only studies that would notably impact the primary EPA draft judgments (i.e., the health effects identified as human health hazards and the final reference values) in the Step 4 draft will be added to the Toxicological Review by EPA prior to finalization. The panel is asked to identify (with justification) any EPA decisions on incorporation or impact that are not supported.

Table I-2 Other studies meeting assessment PECO criteria

Reference | Source^a^ | Assessment topic | Results summary | EPA disposition on incorporation and characterization of impact^b^
PBPK
Fàbrega et al. (2015) | External peer reviewer | PBPK model | This study had been previously identified as describing a PBPK model with parameters for a number of PFAS, including PFDA. However, because of the uncertainties identified early in EPA’s process of developing Toxicological Reviews for multiple PFAS, the model was not considered sufficiently reliable for use in any of the reviews and discussion of the model in the draft PFDA review was inadvertently overlooked. In particular, a general issue with PBPK predictions of tissue distribution for PFAS is now described in the revised Toxicological Review: A key assumption of PFAS PBPK models common to the Fàbrega model is inconsistent with rat PK data, making the prediction of such models in humans uncertain. Further, parameters for PFDA in the Fàbrega model were nominally based on tissue concentration data from cadavers (Pérez et al., 2013), but most of the PFDA data reported by Pérez were below the limit of detection (LOD) and Fàbrega assumed the tissue concentrations were at the LOD. Then tissue/blood partition coefficients were set by comparing those values to blood levels from living human subjects from a separate study, published 6 yr prior to Pérez (Ericson et al., 2007). Comparison of model predictions to validation data was not provided. Hence, the model is considered far too uncertain for application in the Toxicological Review. | Yes. Concerns with the model and the conclusion of high uncertainty, described here, are now included in the Toxicological Review. Since the model was therefore not applied, there is no impact on the risk characterization.

a For literature identified by public commenters, the full comments are available here: https://www.regulations.gov/docket/EPA-HQ-ORD-2019-0287.

b As described in charge question 1, only studies that would notably impact the primary EPA draft judgments (i.e., the health effects identified as human health hazards and the final reference values) in the Step 4 draft will be added to the Toxicological Review by EPA prior to finalization. The panel is asked to identify (with justification) any EPA decisions on incorporation or impact that are not supported.

Table I-3 Studies meeting select categories of supplemental evidence

Reference | Source^a^ | Assessment topic | Description or Results | EPA disposition on incorporation and characterization of impact^b^
ADME
Louisse et al. (2022) | Lit update | ADME | PFDA shown to be a substrate of human renal organic anion transporter 4 (OAT4) w/saturable kinetics. | Yes.; Demonstrates mechanism of saturable resorption in the kidney, which can result in sex-dependent (due to hormonal regulation of OAT4) and dose-dependent urinary clearance (CL). Since human CL is estimated from empirical PK data, there is no quantitative impact on the assessment, but the result provides mechanistic information explaining why urinary CL in humans is much less than predicted based on the glomerular filtration rate alone.
Wang et al. (2018) | Commenter | ADME | Ratio of PFDA and other PFAS in CSF to blood serum in patients (n = 113 for PFDA). | Yes.; Results will not impact HED and RfD calculations, but penetration to the brain is worth noting.
Yao et al. (2023) | Lit update | ADME | Urinary CL in infants was estimated from matched blood and urine samples. | Yes.; CL for PFDA in infants (mean = 0.037 mL/kg-d, median = 0.022 mL/kg-d) in the range of values estimated in the current draft for men (0.039 mL/kg-d) and nonreproductive-age women (0.026 mL/kg-d). CL = 0.026 mL/kg-d was used in the current draft for extrapolation of (mouse) developmental effects and interpretation of human epi studies. Given the similarity in values, incorporation of these new results would not impact results presented in the draft. However, there has been significant uncertainty as to how well the ADME from adults predicts ADME in children, so incorporating these results would help inform an important uncertainty regarding whether CL is consistent across lifestages.
| | | The paper also shows predicted blood concentration in the child from birth to 1 yr of age. | No.; The predicted time-course from birth to age 1 appears to assume intake is constant at that estimated for a newborn and fails to account for infant growth during that time, which is significant. Hence the prediction is considered to be unreliable and not useful to add to the analysis.
Zhang et al. (2022) | Lit update | ADME, metabolomics (cord blood) | Correlation between PFAS levels in cord blood and a postnatal blood sample (median age 2.1 yr, IQR 1.3–3.8 yr) and with metabolite levels in cord blood were evaluated, along with the trend in cord blood vs. birth yr. | No.; For PFDA there is only a weak correlation (r = 0.4, n = 30) between cord blood and postnatal concentration. Considering the range in age of the postnatal sample and that the extent of breastfeeding was not evaluated, hence not factored, the weak correlation is not surprising. While these observations support the assumption in the current analysis that concentrations in young children result from combined in utero and postnatal exposure, it does not change them and would have no quantitative impact on the draft HED calculations.
Blomberg et al. (2023) | Commenter | ADME | Ratio of PFAS in colostrum or breast milk to maternal serum levels. | No.; PFDA was only measured in two samples (individuals) each of colostrum and breast milk in this study, compared with the 50 matched samples analyzed by Liu et al. (2011), so Blomberg does not provide any significant new data for PFDA.
Fromme et al. (2010) | Commenter | ADME | PFAS levels in maternal serum during and after pregnancy, cord blood, infant serum, and breast milk were reported. | No.; Reported PFDA levels in most summary statistics were below the LOQ and correlations among or trends in matched samples were not reported, so the study does not provide any significant new data for PFDA.
Pan et al. (2017) | Commenter | ADME | Ratio of PFAS in maternal serum in each trimester to PFAS concentration in cord serum at delivery was reported and analyzed for correlations with other factors. | No.; Since maternal and fetal/cord serum are likely to change during pregnancy, the nominal interpretation of the data as showing changes in transfer efficiency is highly questionable. Further, the data have no practical impact on the PK calculations used and previous data on maternal/cord PFDA concentration ratios are already presented.
Pan et al. (2019) | Commenter | ADME | PFAS were analyzed in serum and semen. PFDA was present in semen at a level of 2% of that in serum. | Yes.; The study is now described briefly in the section on ADME/distribution in humans, since there are few data on human distribution other than cord blood and placenta, but there is no quantitative impact since semen quality is not an identified endpoint.
Han et al. (2018) | Commenter | ADME | Paternal, maternal, and cord serum measurements.; Cord:maternal serum ratio (medians) of 0.38. | Yes.; This study is now described along with others reporting the distribution between maternal and cord serum. The ratio reported is in the range of other studies previously included, so there is no quantitative impact.
Glynn et al. (2020) | Commenter | ADME | PFDA serum concentration in school children. Boys significantly higher than girls (median 0.22 in girls vs. 0.25 in boys). Onset of menstrual bleeding was a factor for PFHxS and PFOA but not for PFDA. | Yes.; This study is now discussed as part of the analysis of excretion in humans. While the difference between boys and girls may have been statistically significant, it is not large enough to have a quantitative impact and NHANES data analyzed likewise do not show a meaningful (or consistent) difference between human males and females.
Pérez et al. (2013) | External peer reviewer | ADME | Tissue concentration of PFDA in humans (n = 20). PFDA mostly below LOD in liver, bone, lung, and kidney. Interestingly 70% above LOD in brain. No serum/blood or exposure data. | Yes.; The study is now cited, but because many of the measurements were below LOD, quantitative interpretation is not possible. That accumulation seems to be highest in the brain was noted. No impact on HEDs, etc.
Bao et al. (2022) | External peer reviewer | ADME | Maternal serum, placenta, and cord blood measurements of PFDA concentration. | Yes.; Added to discussion of distribution during pregnancy. Only a few other studies reported levels in the placenta, so it is worth comparing these results, but they are consistent with the previously included studies.; Likewise, the distribution to cord blood is consistent with previously evaluated studies. So, inclusion of these data has no impact on the HEDs.
Chen et al. (2022) | External peer reviewer | ADME | Measurement of PFDA in urine and whole blood and estimation of a urinary clearance rate. | Yes.; This is only the third study evaluating urinary clearance (CL) in humans and the mean value estimated is considerably above the other two. A population-weighted mean urinary CL was calculated using results for all three studies and is influenced by these results. The CL is 20% higher than if only results from the other two studies are used but the resulting mean is over 5× higher than the lowest mean, which had been selected in the previous draft. Inclusion of this study influenced the decision to calculate a weighted mean, so the overall impact is significant.
Mechanistic, including Non-PECO Routes of Exposure
Wang et al. (2022) | Lit update | Mechanisms of PFDA-induced adipogenesis in HepG2 cells and 3-t3-Li murine white preadipocytes (liver, cardiometabolic) | PFDA induced triglyceride accumulation by modulating the NLRP3 inflammasome-mediated SREBP1 pathway in the in vitro model systems. | Yes.; Although the results would not change draft judgments, they address a key data gap with respect to understanding potential PFDA-mediated liver metabolic effects in human models (available data mostly from animal models) and inform the key science issue of human relevance of liver effects observed in rodents.
Reo and Adinehzadeh (2000) | Commenter | Phospholipid metabolism (liver) | PFDA affected phosphatidylcholine and phosphatidylethanolamine biosynthesis in rat livers. | No.; Results are consistent with previous findings on the mechanisms of PFDA-induced liver effects in animals but do not inform the key science issue of human relevance of liver effects observed in rodents.
Sun et al. (2023) | Lit update | PPAR-α, −β/δ, −γ (liver) | PFDA showed transcriptional activity toward the dolphin and human PPAR -α, −β, −γ isoforms in HEK cells.
Amstutz et al. (2022) | Lit update | HepG2 cell viability and ROS formation (liver) | PFDA affected cell viability in a dose-dependent manner and increased ROS production.
Ojo et al. (2022) | Lit Update | DNA damage and cell viability in HepG2 cells (cancer, liver) | PFDA caused a dose-dependent decrease in cell viability and a moderate increase in DNA damage. | No.; Results would not change draft judgments or provide additional insights into potential mechanisms of PFDA-induced carcinogenicity or liver toxicity.
Evans et al. (2022) | Lit update | PPAR-α and ER (liver and reproductive) | PFDA showed activity toward the human and rat PPAR-α, −γ receptors in ligand binding assays but no transcriptional activity toward the human ER in vitro. | No.; Results are consistent with previous findings on the interaction of PFDA with these receptors in vitro but do not provide additional information on potential mechanisms of PFDA-induced liver or reproductive effects.
Bjerregaard-Olesen et al. (2016) | Commenter | Xenoestrogenic activity (reproductive) | The association of PFDA and xenoestrogenic activity was examined. | No.; While the study may provide minimal mechanistic insight for PFDA-induced reproductive or endocrine effects, the data would not impact the hazard judgments.
Bjerregaard-Olesen et al. (2014) | Commenter | Xenoestrogenic activity (reproductive) | The association of PFDA and xenoestrogenic activity was examined. | No.; While the study may provide minimal mechanistic insight for PFDA-induced reproductive or endocrine effects, the data would not impact the hazard judgments.
Running et al. (2022) | Lit update | Steroid hormone levels (reproductive, endocrine) | PFDA significantly increased progesterone and 21-hydro-progesterone levels in H295R adrenocortical carcinoma cells but had no significant effects on the levels of androgens, corticosteroids, and estrogens. | No.; While the study may provide minimal mechanistic insight for PFDA-induced reproductive or endocrine effects, the data would not impact the hazard judgments.
Zhao et al. (2023) | Lit update | 11β-hydroxysteroid dehydrogenase 2 activity (endocrine) | The effect of PFDA on human and rat 11β-hydroxysteroid dehydrogenase 2 activity was determined under in vitro and in silico conditions. | No.; While the study may provide minimal mechanistic insight for PFDA-induced reproductive or endocrine effects, the data would not impact the hazard judgments.
Tian et al. (2022) | Lit update | Folate levels (developmental) | The effect of PFDA on folate homeostasis was determined in adolescents. | No.; While the study may provide minimal mechanistic insight on how PFDA exposure may cause developmental/neurodevelopmental effects, such information would not impact the hazard judgment.
Ding et al. (2022) | Lit update | Adipocytokines (developmental) | The association of in utero PFDA exposure and adipocytokines was examined in umbilical cord serum. Leptin levels were decreased. | No.; While the study may provide minimal mechanistic insight on how PFDA exposure may cause developmental/neurodevelopmental effects, such information would not impact the hazard judgment.
Liu et al. (2023) | Lit update | Vitamin D levels (developmental) | The association between PFDA exposure and vitamin D biomarker levels was examined in newborns. | No.; While the study may provide minimal mechanistic insight on how PFDA exposure may cause developmental/neurodevelopmental effects, such information would not impact the hazard judgment.
Zota et al. (2018) | Commenter | Inflammation and aging (immune) | The association of PFDA exposure and inflammation and cellular aging was examined during pregnancy and postpartum. | No.; While the study may provide minimal mechanistic insight for PFDA-induced effects on the immune system, the data would not impact the hazard judgments.
Salo et al. (2019) | Commenter | Β-cell autoimmunity and type 1 diabetes (cardiometabolic) | The association of PFDA exposure, Β-cell autoimmunity, and type 1 diabetes was examined. | No.; While the study may provide minimal mechanistic insight for PFDA-induced cardiometabolic effects, the data would not impact the hazard judgments.
Starling et al. (2020) | Commenter | DNA methylation (cardiometabolic) | The association of PFDA, umbilical cord blood DNA methylation, and cardiometabolic effects was examined. | No.; While the study may provide minimal mechanistic insight for PFDA-induced cardiometabolic effects, the data would not impact the hazard judgments.
Li et al. (2022c) | Lit Update | Toxicity prediction (multiple organs) | PFAS chemicals included PFDA, identified from human serum samples, were screened for toxicity using prediction models. PFDA was positive for multiple organ toxicities (e.g., liver). | No.; While the study may provide minimal mechanistic insight for PFDA-induced effects on multiple organs, the data would not impact the hazard judgments.
Li et al. (2019b) | Commenter | Metabolomics (multiple organs) | The association of PFDA exposure and the metabolome was examined. | No.; While the study may provide minimal mechanistic insight for PFDA-induced effects on multiple organs, the data would not impact the hazard judgments.
Jain and Ducatman (2022) | Lit update | Manganese and selenium levels (serum) | Broad analysis of associations between blood manganese and selenium levels and PFDA concentrations in adults and children (nonspecific to health effects). | No.; No data relevant to draft judgments.
Bashir and Obeng-Gyasi (2022) | Lit Update | Allostatic load (general toxicity) | The association of PFDA and allostatic load was examined in adults. | No.; No data relevant to draft judgments.

ADME: Absorption, Distribution, Metabolism and Excretion; CL: clearance; CSF: cerebrospinal fluid; HEDs: human equivalent doses; HEK: human embryonic kidney; HEPG2: human hepatocellular carcinoma; IQR: interquartile range; LOD: limit of detection; NHANES: National Health and Nutrition Examination Survey; NLRP3; Nod-like receptor family, pyrin domain containing 3; OAT4: renal human organic anion transporter 4; SREBP1: sterol regulatory element binding transcription factor 1.

a For literature identified by public commenters, the full comments are available here: https://www.regulations.gov/docket/EPA-HQ-ORD-2019-0287.

b As described in charge question 1, only studies that would notably impact the primary EPA draft judgments (i.e., the health effects identified as human health hazards and the final reference values) in the Step 4 draft will be added to the Toxicological Review by EPA prior to finalization. The panel is asked to identify (with justification) any EPA decisions on incorporation or impact that are not supported.

9 The State of New Jersey Department of Environmental Protection and the Natural Resources Defense Council (NRDC) submitted 186 studies. Of the 186 studies, 119 studies had been previously identified and can be found in the HERO (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614) database. The remaining 67 studies were screened for PECO criteria and evaluated for potential incorporation and impact on the assessment’s conclusions, as stated above.