# APPENDIX H SUMMARY OF PUBLIC AND EXTERNAL PEER-REVIEW COMMENTS AND EPA’S DISPOSITION

The Toxicological Review has undergone a formal external peer review in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). A public, external peer-review meeting was held July 10, 11, and 13, 2023, which included an opportunity for public comment. The external peer reviewers were tasked with providing written answers to general questions on the overall assessment approach, key conclusions, and areas of scientific controversy or uncertainty. Prior to the external peer review, the Toxicological Review of Perfluorodecanoic Acid and Related Salts was released for public comment (in April 2023). Public comments on the assessment were submitted to the U.S. Environmental Protection Agency (EPA) by June 9, 2023.

Comments made by the external peer reviewers and public commenters, as well as EPA's responses to these comments, are arranged by charge question below. In addition, each charge question includes an overarching summary of the peer-review panel's comments, drawing from the summary language provided in Section 2 of the final peer-review report. In many cases, the comments of the individual reviewers have been synthesized and paraphrased for brevity but when feasible this appendix uses direct language from the external peer-review report and public comments (please consult the final peer-review report (https://ordspub.epa.gov/ords/eims/eimscomm.getfile?p_download_id=547776) for the full text of the panel's comments and consult the EPA docket for the full text of the public comments received: EPA-HO-ORD-2019-0287 (https://www.regulations.gov/docket/EPA-HQ-ORD-2019-0287)). external peer reviewers were asked to prioritize their comments to indicate their relative importance as follows. The prioritization instructions are duplicated below from the IRIS PFDA charge questions to the peer reviewers, which can be found in the public EPA docket (EPA-HQ-ORD-2019-0287):

- Tier 1: Necessary Revisions - Use this category for any revisions you believe are necessary to adequately support and substantiate the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the PFDA Toxicological Review.
- Tier 2: Suggested Revisions - Use this category for any revisions you encourage EPA to implement to strengthen the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the PFDA Toxicological Review.
- Tier 3: Future Considerations - Use this category for any advice you have for scientific exploration that might inform future work. While these recommendations are generally outside the immediate scope or needs of the PFDA Toxicological Review, they could inform future reviews or research efforts.

Appendix H lists all Tier 1 Recommendations and Tier 2 Suggestions from the external peer reviewers, organized by charge question. Tier 1 Recommendations and Tier 2 Suggestions were considered in light of the extent to which those suggestions would impact the conclusions or quantitative analyses of the assessment, consistency across committee members in raising the suggestion, and the level of effort to implement. For this assessment, Tier 2 suggestions deemed impactful to the toxicity value conclusions were implemented. Tier 3 Future Considerations are generally outside the immediate scope or need of the Toxicological Review but may inform future analyses; for the specific Tier 3 considerations received, these comments ultimately did not inform the analyses in this assessment and are therefore not discussed in this appendix (these comments are included in the external peer-review report linked above). Text from the report that could be interpreted as advice or suggestions to EPA, but which was not tiered, was considered by EPA as Tier 3.

Public comments made on topics raised by the external peer reviewers are noted along with the external peer-review comments. When comments from the public and peer-review panel on a topic conflicted, the recommendations of the panel are prioritized. Additional public comments not raised by the peer reviewers are included in a separate section at the end of each charge question section.

External peer-review and public comments regarding requests for additions of clarifying text or editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this appendix.

## H.1 CHARGE QUESTION 1 – LITERATURE SEARCH METHODS AND DOCUMENTATION

1. The Toxicological Review for PFDA describes and applies a systematic review protocol for identifying and screening pertinent studies. The protocol is described in brief detail in Section 1.2.1 and in full detail in Appendix A. Please:
  a) Comment on whether the literature search strategy and screening criteria for PFDA are appropriate and clearly described.
  b) Identify additional peer-reviewed studies of PFDA that EPA should consider incorporating prior to finalizing the assessment.

EPA synthesized the literature published through April 2022 in the external review draft and has been monitoring newly identified studies (i.e., studies identified by EPA or the public that meet the PECO criteria or otherwise inform key assessment conclusions, but which were not addressed in the external review draft, for example due to publication after April 2022). EPA will characterize these studies in a document that will be provided to the peer-review panel and the public and, following the review, included as an appendix to the assessment prior to finalization (see Appendix I). The characterization will focus on EPA's judgment of whether the studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft. Following receipt of this additional document after the review is underway, please:

c) Review EPA's characterization and provide tiered recommendations regarding which studies, if any, would have a material impact on the draft's conclusions and should be incorporated into the assessment before finalizing, as well as your interpretation of the impact of those studies to be incorporated.

### H.1.1 External Peer-Review Comments on Literature Search Methods and Documentation

#### Peer-Review Comment Summary

- Charge question la: While several reviewers provided Tier 1 and Tier 2 comments with suggested specific revisions (see below), all nine reviewers agreed that the literature search strategy and screening criteria are clearly described, and the process is well documented.
- Charge question 1b: The majority of the panel (five reviewers) did not identify any additional studies of PFDA for EPA to consider prior to finalizing the assessment, while several reviewers provided specific Tier 1 or Tier 2 comments (see below, noting there were also Tier 3 comments on this topic) on additional studies.
- Charge question 1c: The majority of the panel (eight reviewers) did not note any material impact of the new studies on the draft's conclusions, although several Tier 1 and Tier 2 comments were provided (see below, noting there were also Tier 3 comments on this topic), primarily related to clarifying how newer literature will be tracked or incorporated.

#### Tier 1 Necessary Revisions

Comment: A reviewer provided the following comments on the PECO criteria for literature screening: 1) “In the Evidence column for Populations, Human: Recommend adding text similar to for Animal, '(including preconception, in utero, lactation, peripubertal, and adult stages)' or otherwise assure inclusion of sensitive developmental windows including those relevant to mammary gland development (e.g., duration of lactation as an outcome), fertility, infant exposure, etc.”; 2) “In the Evidence column for Outcomes, '(Note: Other than genotoxicity studies, studies including only molecular endpoints [e.g., gene or protein changes; receptor binding or activation] or other nonphenotypic endpoints addressing the potential biological or chemical progression of events contributing towards toxic effects will be tracked as potential supplemental material [e.g., for evaluating key science issues; Section 2.4 of the protocol]).' Recommend clarifying here or elsewhere how vaccine immune titer is a functional measure of adaptive immune response and therefore a phenotypic outcome.”

EPA Response: EPA believes the wording of the existing PECO statement for “Population” captures the literature noted by the reviewer and did not revise this portion of the PECO statement. Similar to the description of the animal population, the PECO statement in Table 1-4 makes note of sensitive human populations stating, “any population and lifestage (occupational or general population, including children and other sensitive populations).” Regarding the use of antibody responses for immunotoxicity, a sentence was added to the “Outcome" portion of the PECO table to clarify that functional immune measures (e.g., antibody response) are considered phenotypic outcomes. Further, the section on immune effects (see Section 3.2.2) provides a justification for using reduced antibody levels as a functional measure of immunosuppression that could indicate a general increase in susceptibility to infectious diseases (i.e., not limited to those studied).

Comment: Four reviewers asked for clarification on the reasons for excluding 595 studies as “Not Relevant to PECO" at the title and abstract level as done for studies that were excluded at full text screening (Figure 2-1).

EPA Response: Studies are excluded if they do not meet all PECO criteria and text has been added to the assessment for clarification. During screening, most studies are excluded because they do not meet any or only meet a few of the PECO criteria. Thus, a single screened out study typically has multiple reasons for exclusion which is unwieldy to document, especially at the title and abstract level when screening may be needed for thousands of studies. Some of the studies that did not meet all PECO criteria were considered to have potentially relevant supplemental information and were tagged as such. The annotation used in the assessment is consistent with the convention in the IRIS Handbook (U.S. EPA, 2022b). A sentence was added to Section 2.1 to clarify that excluded studies “did not meet the PECO and did not contain potentially relevant supplemental information, ” …

Comment: A reviewer suggested further explanation on the health effects that were included and excluded for extraction into HAWC for epidemiological studies (Section 1.2.4. page 33, line 34).

EPA Response: The IRIS Handbook provides for flexible approaches for data extraction, to include extraction into HAWC or tabular presentation. Details on how data extraction is approached for studies that meet PECO criteria can be found in Section 1.2.4 of the Toxicological Review and Section 8 of the PFAS protocol cited in Appendix A of this document. Specifically, the decision whether to extract epidemiological studies in HAWC was based primarily on whether data visualizations were determined necessary to understand the evidence synthesis judgments. Text has been added to clarify this rationale in Section 1.2.4. When visualizations were not used, results were instead extracted into tables in the assessment when relevant.

Comment: One reviewer identified three additional epidemiological studies for consideration, including a study on developmental effects (Padula et al., 2023) and two studies on lactation duration (Timmermann et al., 2017; Romano et al., 2016).

EPA Response: EPA identified the (Padula et al., 2023) study in its March 2023 literature search update and determined that its incorporation into the draft is not necessary given the results of the study do not influence the current draft judgment for either gestational duration or fetal growth restriction (see Appendix I). In addition, the methods describing consideration of newly identified studies are laid out in Section 1.2.1 of the main document, which has been edited for clarity.

Studies on breastfeeding duration (Rosen et al., 2018; Timmermann et al., 2017) and others identified on this outcome) have been added to Section 3.2.5. These studies were incorporated because they were viewed as relevant to a key assessment uncertainty. Namely, few studies (for any PFAS) are available on this specific outcome and potential effects of PFAS on this outcome have been hypothetically linked to impacts on mammary gland development, an outcome affected by certain PFAS in experimental studies (e.g., reviewed in: https://www.ncbi.nlm.nih.gov/pmc/articles/PMC7968861/). Specifically, for the Toxicological Review, a subsection was added to synthesize the results of the epidemiological studies focusing on PFDA effects on breastfeeding duration. Additionally, a table (see Table 3-27) was added to present the results of these studies. Finally, this outcome was added to the evidence profile table for PFDA exposure and female reproductive effects.

Comment: A reviewer provided the following comment on the additional studies submitted during public comment, “EPA should consider (Tier 1 necessary revision) whether or not the results of the studies recommended by public commenters should be incorporated into the assessment utilizing relevant practical criteria (e.g., based on their potential impact (if any) on data gaps, assessment conclusions, and/or toxicity values). However, it appears that EPA has already done so (see EPA characterization of studies identified after public release of the draft IRIS Toxicological Review of Perfluorodecanoic Acid (PFDA, CASRN 335-76-2) and Related Salts).”

EPA Response: EPA confirms the reviewer is correct that EPA has already reviewed new studies identified during public comment and provided a judgment on the material impact on key assessment decisions (i.e., hazard identification and dose-response assessment) to decide whether to include such studies in the revised assessment prior to finalization. This information was provided to peer reviewers and added to the public docket and has also been included in the supplemental information to the Toxicological Review of PFDA (see Appendix I).

Comment: Regarding EPA's characterization of the studies identified after release of the External Peer-review Draft, a reviewer noted “Tier 1 recommendation is to clarify overall how the recent updated literature review will be incorporated into the current draft, Tier 2 recommendation deals with clarification of how those papers identified as YES [i.e., materially impactful], will be incorporated into the specific relevant sections of the report"

EPA Response: Text was edited in Section 1.2.1 of the Toxicological Review to clarify the strategy for incorporating new studies, “The literature through March 2023 was screened while the document was undergoing public comment. The results of this literature update and any additional unscreened studies identified during public comment and external peer review were screened against the PECO criteria and presented in Tables I-1, I-2, and I-3 of Appendix I in the assessment. The tables provide the identified studies that met PECO criteria or certain supplemental evidence categories (i.e., in vivo mechanistic or MOA studies, including non-PECO routes of exposure and populations; in vitro and in silico models; and absorption, distribution, metabolism, and excretion (ADME) and pharmacokinetic [PK] studies) and EPA's judgment and supporting rationale on whether the studies would have a material impact on the assessment conclusions (i.e., identified hazards or toxicity values) presented in the public comment draft. New studies judged influential in informing assessment conclusions and data gaps were incorporated into the relevant section of the assessment prior to finalization.”

Comment: Three reviewers suggested that the exposure section be updated and expanded. One reviewer provided several references for inclusion.

EPA Response: Several updates were made to this section using information from the following recent information sources: https://echo.epa.gov/trends/pfas-tools, (Holder et al., 2023), and NHANES - National Health and Nutrition Examination Survey Homepage (cdc.gov). However, EPA notes that a comprehensive evaluation of exposure is outside the scope of IRIS assessments. The background information described in Section 1.1 is an overview and is not intended to provide a comprehensive description of the available information on PFDA and related salts, and information on human exposure is tagged as supplemental information during the screening process.

#### Tier 2 Suggested Revisions

Comment: A reviewer suggested “Listing any major research activities that are [on]going would be useful (Tier 2) because of the number of people contributing to the literature.”

EPA Response: The Agency's broader strategic roadmap (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021-2024) documents ongoing activities at EPA aimed at safeguarding communities from PFAS contamination, including evaluation of potential human health effects associated with exposure to individual PFAS and PFAS mixtures. Text was added to the Executive Summary of the draft Toxicological Review to better emphasize this resource and highlight a few relevant activities.

### H.1.2 Public Comments on Literature Search Methods and Documentation

Comment: A commenter noted discrepancies in the number of studies identified in the Toxicological Review and in the PFAS-Tox Database and provided a list of additional human studies for EPA's consideration noting, “… In order to better, understand where the differences in results arise, it would be helpful if EPA would provide a list of all excluded studies and the reason for exclusion.” The reviewer added, “… While some of the studies that were included in the PFAS-Tox Database may be out of the scope of the EPA's analysis, it would be helpful to understand EPA's decision process on these studies. For example, Pan et al., found that PFDA was associated with increased DNA fragmentation index and high DNA stainability (a marker of the percentage of sperm with immature chromatin) in semen. ^(9)^ Semen evaluations were considered in Section 3.2.4 of the Draft Toxicological Review, and it is unclear why this study was not included. EPA should review the submitted attachment and evaluate if additional human studies should be included in the Toxicological Review.”

EPA Response: EPA has reviewed the studies included in the PFAS-Tox Database, including the available human studies, against the PFDA assessment PECO criteria; the results of this screening are included on the HERO project page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614). As mentioned above, EPA reviewed the studies identified during public comment and provided a judgment on the material impact on key assessment decisions (i.e., hazard identification and dose-response assessment) to decide whether to include such studies in the revised assessment prior to finalization. This information was provided to peer reviewers and has also been included in the supplemental information to the Toxicological Review (see Appendix I). Regarding the study highlighted by the commenter, EPA documented the decision not to include Pan et al., (2019, 6315783) since the evidence for semen parameters was inconsistent and this study would not influence the assessmenťs conclusions for male reproductive effects or otherwise impact key assessment conclusions or uncertainties (see rationale in Table I-1 in Appendix I).

Comment: The same commenter noted seven missing studies on breastfeeding duration and the overall lack of evaluation of this human health endpoint in the draft Toxicological Review, “Given the importance of breastfeeding and its association with many other health impacts, this is a major oversight. EPA should review the submitted attachment and consider summarizing the available evidence that PFDA may be associated with shortened duration of breastfeeding.”

EPA Response: As described above, EPA evaluated studies identified after release of the draft Toxicological Review for public comment and as a result of this analysis, several studies on breastfeeding duration have been added to the Toxicological Review (see Section 3.2.5). Specifically, a subsection was added to synthesize the results of the eight epidemiological studies focusing on PFDA effects on breastfeeding duration. Additionally, a table (see Table 3-27) was added to present the results of these studies. Finally, this outcome was added to the evidence profile table for PFDA exposure and female reproductive effects.

Comment: Regarding supplemental evidence, the same commenter suggested, “In general, studies presumably marked as supplemental materials are not consistently referred to and discussed in the document. EPA should provide further guidance for when it will make use of available supplemental materials. The list of nonmammalian models or animals that were exposed through non-oral routes, for example, is not readily accessible, or cited in the Draft Toxicological Review. EPA should better mention and summarize these mechanistic studies, in order to more fully describe the potential effects of PFDA.” The commenter also identified 72 studies in animals exposed to PFDA via intraperitoneal (i.p.) injection that were submitted to EPA for consideration.

EPA Response: EPA has reviewed the 72, i.p. injection studies and found that only one study had not been previously identified (Reo and Adinehzadeh, 2000). EPA decided not to incorporate this study into the assessment because it does not impact assessment conclusions or inform key data gaps (see Table I-3 in Appendix I for more details). Screening decisions for the remaining studies can be found in the HERO project page for PFDA (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614), which provides a list of all studies tagged as supplemental.

Section 1.2 of the Toxicological Review and the Systematic Review Protocol for the PFAS IRIS Assessments (see Appendix A) outline consideration of supplemental materials. Not every study tagged as supplemental is described or cited in the Toxicological Review draft. Cited supplemental material studies are typically those that address specific scientific issues and uncertainties. This is the case for some of the i.p. studies submitted by the commenter that were not included because they would not help bring clarity to the core areas of uncertainty in the assessment (see Section 2.4 of the PFAS protocol). Additional information on the IRIS Program approach to categorizing and considering supplemental studies can be found in the IRIS Handbook (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370).

Comment: The same commenter added, “The use of studies tagged as supplemental is also important in the evaluation of carcinogenicity. Notably, we identified several studies that likely were tagged as supplemental studies by EPA, which may be informative, especially should EPA consider using the Key Characteristics of Cancer framework, which has been used by agencies such as California's Office of Environmental Health Hazards. In particular, the study by Benninghoff et al. 2012, which evaluated tumor promotion in trout, was important in OEHHA's analysis of the carcinogenicity of PFOS. PFDA was also evaluated in the study by Benninghoff et al.” The commenter listed seven studies specific to PFDA that may be of interest for the evaluation of carcinogenicity.

EPA Response: As is the case for most PFAS evaluated by EPA to date, EPA concluded that there is inadequate information to assess the carcinogenic potential of PFDA by any route of exposure based primarily on consideration of the human and animal toxicological literature. As stated in Section 3.3.1, the scope of the mechanistic analysis for carcinogenicity focused on genotoxicity based on the sparse and low confidence human and animal studies available and the insufficient information for evaluation of alternative carcinogenic mechanisms. EPA notes that one of the seven studies (Liu et al., 2019) identified by the commenter has already been synthesized as part of the genotoxicity evaluation for PFDA. The remaining studies on other potential mechanisms are tagged as potentially relevant supplemental information but are not cited in the Toxicological Review because they would not impact assessment hazard or dose-response conclusions. A list of supplemental studies for PFDA can be found in the HERO project page for this Toxicological Review (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614).

## H.2 CHARGE QUESTION 2 – NONCANCER HAZARD IDENTIFICATION

2 For each health effect considered in the Toxicological Review and outlined below, please comment on whether the available data have been clearly and appropriately synthesized to describe the strengths and limitations, including whether the presentation and analysis of study results are clear, appropriate, and effective to allow for scientifically supported syntheses of the findings across sets of studies. Please comment on whether the study confidence conclusions for the PFDA studies are scientifically justified, giving appropriate consideration to important methodological features of the assessed outcomes.^7^ Please specify any study confidence conclusions that are not justified and explain any alternative study evaluation decisions. For each, please also comment on whether the weight-of-evidence decisions for hazard identification have been clearly described and scientifically justified. Note that the data from studies considered informative to the Toxicological Review are synthesized in the relevant health effect-specific sections and available in the Health Assessment Workspace Collaborative (HAWC).
  a) For liver effects, the Toxicological Review concludes that the available evidence indicates PFDA exposure is likely to cause liver effects in humans given sufficient exposure conditions, on the basis of a series of short-term studies in rats and mice demonstrating consistent and coherent effects with a clear biological gradient. The liver findings for PFDA were similar to those for other structurally related long-chain PFAS and determined to be adverse and relevant to humans.
    i. Additional considerations influenced the liver effects hazard identification decisions. Appendix A (Systematic Review Protocol for the PFAS IRIS Assessments) outlines the human relevance of hepatic effects in animals that involve PPARα receptors as a key science issue. To the extent supported by the PFDA literature (and to a lesser extent, literature for other PFAS), the Toxicological Review evaluates the evidence relevant to the potential involvement of PPARα and non-PPARα pathways with respect to the reported liver effects. The Toxicological Review ultimately concludes evidence from in vivo and in vitro studies support a potential role for multiple pathways operant in the induction of hepatic effects from PFDA exposure, although how those pathways interact within a mode of action (MOA) cannot be specifically determined.
  b) For immune effects, the Toxicological Review concludes that the available evidence indicates PFDA exposure is likely to cause immunosuppression in humans given sufficient exposure conditions, primarily on the basis of consistent evidence of reduced antibody responses from two epidemiological studies in children and one study in adults. Although some evidence for coherent immunomodulatory responses consistent with immunosuppression was identified in short-term animal studies, the animal evidence overall is uncertain. The Toxicological Review concludes the immune effects are considered relevant to humans as the judgment is based on studies in humans.
    i. For nearly all epidemiology studies of PFDA, there is potential that exposure to other highly correlated PFAS could contribute to the observed effects. The evidence synthesis for potential PFDA-induced immune effects included evaluation of the potential for confounding across PFAS as well as other sources of confounding and, on the basis of the available data, determined that residual confounding could explain part of the observed effect, but concern was minimal, and it was unlikely to fully explain the associations seen in the literature.
  c) For developmental effects, the Toxicological Review concludes that the available evidence indicates PFDA exposure is likely to cause developmental effects in humans given sufficient exposure conditions, based primarily on consistent findings of dose-dependent decreases in fetal weight in mice gestationally exposed to PFDA supported by some coherent evidence of decreased birth weight from studies of exposed humans in which PFDA was measured during pregnancy, although uncertainties in the available epidemiological evidence reduced the impact of these latter findings. The Toxicological Review concludes the developmental effects in mice are considered relevant to humans given similar findings of fetal growth restriction in mice and humans.
    i. As described in question 3.c and the footnote to 3.c, the evidence synthesis for potential PFDA-induced developmental effects considered potential confounding factors and concluded that confounding across PFAS or from other potential sources of bias (e.g., pregnancy hemodynamics in studies that measured PFDA during or after pregnancy) introduce significant uncertainty. These sources of uncertainty ultimately reduce the strength of the available human evidence to slight for an evidence base that might otherwise be interpreted as moderate.
  d) For male reproductive effects, the Toxicological Review concludes that the available evidence indicates PFDA exposure is likely to cause male reproductive effects in humans given sufficient exposure conditions, based on coherent evidence in adult male rats exposed to PFDA for 28 days. Although no direct information on the human relevance of the animal evidence is available, the findings in animals are presumed to be relevant on the basis of the conserved role of androgen-dependent pathways in male productive functions across species.
  e) For female reproductive effects, the Toxicological Review concludes that the available evidence indicates PFDA exposure is likely to cause female reproductive effects in humans given sufficient exposure conditions, based primarily on coherent evidence from a 28-day study in adult female rats. Although human studies are available examining associations between PFDA and female reproductive toxicity (e.g., fecundity), the results were mostly null, possibly due to their low sensitivity for observing effects. The Toxicological Review concludes the female reproductive effects are considered relevant to humans given that mechanisms of female reproduction are similar between rats and humans. Available evidence indicates PFDA exposure is likely to cause male reproductive effects in humans given sufficient exposure conditions, on the basis of coherent evidence in adult male rats exposed to PFDA for 28 days. Although no direct information on the human relevance of the animal evidence is available, the findings in animals are presumed to be relevant on the basis of the conserved role of androgen-dependent pathways in male productive functions across species.
  f) For cardiometabolic effects, the Toxicological Review concludes that the available evidence suggests but is not sufficient to infer that PFDA exposure may have the potential to cause cardiometabolic effects in humans given sufficient exposure conditions, on the basis of associations between PFDA and serum lipids, adiposity, cardiovascular disease, and atherosclerosis in a few epidemiological studies. However, the evidence is largely inconsistent across studies, which adds considerable uncertainty. Evidence in experimental animals was indeterminate.
  g) For neurodevelopmental effects, the Toxicological Review concludes that the available evidence suggests but is not sufficient to infer that PFDA exposure may have the potential to cause neurobehavioral effects in humans given sufficient exposure conditions, on the basis of associations between PFDA and outcomes related to attention and behavior in epidemiological studies. However, the evidence is largely inconsistent across studies, which adds considerable uncertainty. No evidence was found in experimental animals to inform this outcome (indeterminate).
  h) For endocrine, urinary, and other noncancer effects (i.e., hematological, respiratory, digestive, dermal, musculoskeletal, and nervous systems), the Toxicological Review concludes there is inadequate evidence to determine whether PFDA exposure has the potential to cause these effects in humans on the basis of the sparsity of available evidence.

### H.2.1 External Peer-Review Comments on Hepatic Effects

#### Peer-Review Comment Summary

The majority (seven) of reviewers commented that the available data are clearly and appropriately synthesized, and study confidence conclusions are scientifically justified and appropriate, including with regard to characterizing the PPPRα. One reviewer disagreed with the characterization of evidence of liver effects in human studies as slight and noted that evidence is between slight and moderate and provided related tiered comments (see below). While another reviewer generally noted agreement with EPA's text on liver effects, they provided tier 1 and 2 comments on EPA's analyses of human relevance and adversity (see below).

#### Tier 1 Necessary Revisions

Comment: A reviewer commented, “… EPA should: (1) attempt to scientifically justify whether the mouse or rat is likely most biologically representative of humans such that the same or similar effects (hepatic, etc.) are expected in humans at similar doses when converted to human equivalent doses (HEDs); and (2) in the event (1) cannot be established with sufficient scientific confidence, acknowledge within the assessment that the choice of the most appropriate laboratory animal model for prediction of PFDA-induced adverse effects in humans has not been scientifically established (i.e., is not ‘settled science') but rather species selection is based on policy.”

EPA Response: In response to the reviewer's comment and to highlight adherence to Agency guidelines, the following sentence was added to Section 3.2.1, “This assumption is consistent with EPA's review of RfD/RfC methodology from 2002 (EPA, 2002).” For additional context, Section 3.2.1 and Appendix D provide a detailed synthesis and evaluation of the available mechanistic evidence from in vivo and in vitro model systems for PFDA-induced liver effects to address specific issues surrounding the adversity and human relevance of the hepatic responses observed in rodents. Specifically with regards to the issue of using rats as a human health model for PFDA-induced hepatic effects, the Toxicological Review concluded, “Given that the precise role of PPARα in the non-cancer liver effects of PFDA remains largely unknown and the evidence supporting involvement of both PPARα-dependent and independent pathways, the effects observed in animals are considered potentially relevant to humans.”

Comment: The same reviewer noted that the statement from Section 2.4.2 of Appendix A, “Activation of the peroxisome proliferator-activated receptor alpha (PPARα) by PFAS has been reported, with in vitro evidence that the potency of human and mouse PPARα activation is positively correlated with increasing PFCA chain length up to C9 (no human receptor activation was noted for PFDA…), " contradicts with another statement in the main Toxicological Review (page 3–50, line 5) which indicates, “PFDA can activate the human PPARα in vitro….” The reviewer recommended that “EPA should resolve this apparent discrepancy.”

EPA Response: The text on evidence integration in Section 3.2.1 has been edited for clarity, “PFDA can activate the human PPARα in vitro but it exhibits less/no sensitivity toward the human isoform in comparison with other mammalian species in some studies.” As noted in the section on summary of mechanistic studies for PFDA under Section 3.2.1, evidence of human PPARα activation in vitro by PFDA has been demonstrated across multiple studies using primary and immortalized human liver cell lines and in a receptor binding study. However, reduced or no sensitivity toward the human PPARα compared with the mouse, Baikal seal and polar bear isoforms has also been documented in some studies (including the one referenced by the reviewer).

#### Tier 2 Suggested Revisions

Comment: A reviewer disagreed with evidence synthesis judgement for hepatic effects from human studies stating, “The overall determination that ‘slight evidence' of liver effects in human [studies] (exposure duration not mentioned) is inconsistent given the positive effects observed 4 of 5 studies for PFDA and ALT. The finding of an association is largely consistent with the extensive literature on other longer chain legacy PFAS and liver effects. The subsequent sentence saying that the results lack coherence and mentions other (unnamed) biomarkers in humans is therefore unclear. Overall, this section would be clearer if it clearly separated the determinations from the human and the animal data, then discussed integration and consistency (or lack thereof) between the two data types.” The reviewer thought the descriptor probably lay between slight and moderate for the human evidence given the extensive evidence for related PFAS. The reviewer also added, “I agree that the mechanistic evidence supports the observed effects, which increases confidence in the conclusions and thus the writing on weight-of-evidence determination (WOE) needs to be clearer on what a scientifically justified finding is for this endpoint.”

EPA Response: EPA agrees that the human evidence for this health effect is borderline between slight and moderate. Based on the reviewer's feedback, the studies identified in the literature search update were added to see if they clarified the judgment. Discussion was also included on the potential for confounding across PFAS, which is typically included for effects with moderate or higher evidence. This analysis indicated that there is serious concern for potential confounding by PFNA exposure. Overall, the judgment remains slight for human studies, but the text has been revised to clarify the rationale (see Section 3.2.1 of the Toxicological Review).

Comment: The same reviewer suggested clearly stating the human relevance of the 28-day animal study given the time needed to reach steady state.

EPA Response: The PK analysis indicates that rats in the NTP 28-day study probably did not reach steady state. However, determinations regarding human relevance depend on whether or not the mechanism of toxicity is relevant to humans, not the dosimetric extrapolation across species. The text in Section 3.2.1 has been edited to clarify statements regarding the human relevance of the animal data. Additionally, Section 3.1.7 discusses the approach for dosimetric extrapolation from the 28-day rat study to humans, which has been revised to use observed PFDA concentrations in rats from the NTP study and to no longer assume steady state. But the revision of the dosimetric adjustment only has a quantitative impact on the value of the HED and does not alter the relevance of the endpoint to human health.

Comment: While in agreement with EPA's overall hazard characterization for PFDA-induced liver effects, a reviewer suggested that “… EPA should explicitly show how the Hall et al. (2012) criteria for adversity are met. For example, while fold increases in biomarkers of liver dysfunction (e.g., bilirubin, bile acids/salts) are explicitly discussed on p. 3–48 (lines 36–38), the fold increases needed to fulfill a second criterion (e.g., in ALT or ALP) are not explicitly discussed on lines 34–35 (e.g., a two- to threefold increase in ALT or biomarkers of hepatobiliary damage such as AST, ALP and y-glutamyltranspeptidase [γGT]; Tables 3-7 and 3-8 are relevant).”

EPA Response: Section 3.2.1 provides specific considerations for evaluating potentially adaptive versus adverse liver effects induced by PFDA exposure, including the (Hall et al., 2012) criteria. Hall et al. (2012) indicated that concordant histopathological evidence of degenerative or necrotic changes (e.g., hepatocyte necrosis, fibrosis, inflammation, steatosis, biliary degeneration, necrosis of resident cells within the liver) can be used to support the argument that liver weight/hepatocyte enlargement are adverse (Hall et al., 2012). The evidence for PFDA across two high confidence 28-day gavage studies in rats shows a clear pattern of increased hepatocyte damage/injury with dose, ranging from cytoplasmic changes to hypertrophy to necrosis (Frawley et al., 2018; NTP, 2018). The necrotic lesions were accompanied in some cases by evidence of an initial inflammatory response (NTP, 2018) and, although these changes were characterized as minimal, the findings indicate some degree of structural degeneration considered adverse. Consistent with these observations, steatosis, necrosis, edema, and degeneration were reported in low confidence short-term oral studies in rats and mice at higher PFDA doses (Wang et al., 2020; Kawashima et al., 1995).

Hall et al. (2012) also indicated that clinical markers of liver injury can provide evidence in support of adversity, considering dose-dependent and biologically significant changes in at least two of the following parameters: two- to threefold increase in ALT; a biologically significant change in biomarkers of hepatobiliary damage (e.g., AST, ALP and γ-glutamyltranspeptidase [γGT]; a biologically significant change in biomarkers of liver dysfunction (e.g., albumin, bilirubin, bile acids/salts and coagulation factors). PFDA increased ALT levels in female rats in a high confidence short-term study (NTP, 2018) and although the increases in circulating ALT levels were relatively small (20%-44% or 1.2- to 1.4-fold), concordant changes in other clinical biomarkers occurred in rats that are consistent with the (Hall et al., 2012) criteria for adversity (i.e., dose-dependent increases in levels of AST, ALP, bile salts/acids and bilirubin). Correspondingly, large increases in ALT (338% or 4.4-fold) and AST (649% or 7.5-fold) were reported in mice that exhibited liver lesions after exposure to a high dose of PFDA (13 mg/kg-day) (Wang et al., 2020).

Overall, the evidence for PFDA-induced liver effects in animals meets all the Hall (2012, 2718645) criteria for adversity. Text was added to Section 3.2.1 for clarity and discussion of specific fold changes for all liver clinical markers.

Comment: The same reviewer recommended, “… EPA should consider additional tables and/or figures that would help readers visualize important EPA conclusions, such as ‘coherent changes in serum biomarkers, histopathology, and liver weights' cited in Table 3-11 [Table 3-10 in the revised Toxicological Review].”

EPA Response: A figure displaying changes across histopathology, serum biomarkers and organ weight endpoints has been added to Section 3.2.1 in the discussion on evidence integration and to Table 3-10.

### H.2.2 Public Comments on Hepatic Effects

Comment: One commenter agreed with the overall conclusion that the liver effects of PFDA in rodents should be considered adverse and relevant to humans but disagreed with the statement that the biological significance of the small increases in alanine aminotransferase (ALT) in humans is unclear, noting that “… The EPA Science Advisory Board (SAB) PFAS Review Panel provided a detailed rationale as to why relatively small increases in ALT, including those associated with PFAS, should be considered adverse…" Similarly, another commenter recommended the following “When evaluating the epidemiological data for hepatic effects, I encourage EPA to consider reviewing a new paper regarding the use of clinical consensus cutoffs compared with statistical cutoffs for abnormal values.”

EPA Response: Text was added to the synthesis regarding the adversity of the changes in ALT (see Section 3.2.1 of the Toxicological Review).

Comment: Another commenter raised concerns about “… Uncertainty surrounding the utility of animal data for human health assessment based on interspecies differences in the interaction of PFAS with peroxisome proliferator-activated receptor (PPAR)-alpha (PPARα) and the applicability of environmental concentrations in this interaction.”

EPA Response: A detailed evaluation of the available mechanistic evidence, including the potential role of PPARα in the liver toxicity of PFDA and its implications to human health was provided in Appendix D and in the synthesis of mechanistic studies and supplemental information under Section 3.2.1. The available data indicate a likely role for both PPARα-dependent and -independent mechanisms in the liver effects of PFDA in animals. Existing evidence from in vitro studies and animal models considered more relevant to humans with respect to PPARα sensitivity suggest that some responses may be conserved across species (including activation of relevant nuclear receptor pathways [PPARα/γ, PXR and FXR] and outcomes related to hepatocellular stress, mitochondrial damage, lipid accumulation and liver enlargement). As such, the Toxicological Review concluded “Given that the precise role of PPARα in the noncancer liver effects of PFDA remains largely unknown and the possible involvement of PPARα-dependent and independent pathways, the effects observed in animals are considered potentially relevant to humans.” A majority of the external reviewers agreed with this conclusion as noted in the external peer-review report, “Seven [of nine] reviewers commented that available data are clearly and appropriately synthesized and study confidence conclusions are scientifically justified and appropriate, including with regard to characterizing the PPPRα.”

Comment: A commenter noted, “it is unclear why the evidence of PFDA-induced liver effects was judged to be ‘moderate' rather than 'robust.' As discussed in the paragraph that begins on line 12, the available animal data supports the conclusion that PFDA causes liver toxicity. Although there are no studies with exposure durations of longer than 28 days, the results of such studies would not be anticipated to contradict the conclusion that PFDA causes liver toxicity based on the shorter studies.”

EPA Response: The ORD Staff Handbook for Developing IRIS Assessments (U.S. EPA, 2022b) defines the evidence synthesis judgment of robust animal evidence as follows, “The set of high or medium confidence, independent experiments (i.e., across laboratories, exposure routes, experimental designs [for example, a subchronic study and a multigenerational study], or species) reporting effects of exposure on the health outcome(s).” While the database for PFDA-induced liver effects includes several short-term studies via the oral route, the primary evidence for coherent liver effects comes from two high/medium confidence studies from the same laboratory, species, and exposure design. The text in Section 3.2.1 has been edited to clarify the database limitations and uncertainties that resulted in an evidence synthesis judgment of moderate for animal studies, “The evidence base for liver effects in animals consists primarily of two high/medium confidence 28-day studies in S-D rats conducted by NTP that showed concordant effects. Other available short-term studies provided support for PFDA-induced liver effects across different laboratories and species but had issues with incomplete reporting that resulted in a low confidence rating, evaluated limited endpoints, and/or tested higher doses associated with general systemic toxicity, which add some uncertainty. Additional studies via relevant exposure routes and experimental designs (most prominently subchronic and chronic exposure studies) examining potential liver effects of PFDA exposure are needed to increase confidence in the evidence base.” It is also worth noting that a majority of the external peer reviewers (seven of nine reviewers) agreed with EPA's synthesis and characterization of the available evidence for liver effects.

### H.2.3 External Peer-Review Comments on Immune Effects

#### Peer-Review Comment Summary

In reference to charge question 2b, the majority of the peer reviewers agreed with EPA. Two reviewers agreed with EPA's overall conclusions and had no Tier 1 or 2 recommendations. Five reviewers agreed with EPA's overall conclusions but also made some suggestions for improvement (see below) and one reviewer also provided tiered recommendations but did not state explicit agreement or disagreement with EPA on this charge question. One reviewer disagreed with EPA's conclusion on the strength of evidence for human immunosuppression from the epidemiological studies, citing several Tier 1 and Tier 2 concerns (see below).

During the peer-review meeting, five reviewers noted that discussion of mixtures and confounding needed to be further developed in the document (Tier 1 or 2), with one reviewer noting that confounding effects from other exposures could impact estimates used to derive RfDs (see charge questions 3 and 4), and another reviewer (the reviewer that disagreed with EPA's evidence integration judgment) arguing that issues of mixtures and confounding in the epidemiology studies, combined with the low effect estimates, precluded the use of these studies for quantitative risk assessment and derivation of toxicity factors. This reviewer also did not agree that the measures of immunosuppression (titers) were clinically significant, particularly for rare diseases such as diphtheria and tetanus, although other reviewers agreed with the use of immune titers as an appropriate endpoint (see below and charge questions 3 and 4).

#### Tier 1 Necessary Revisions

Comment: Two reviewers asked for more clarity/explanation on the issue of confounding from PFAS co-exposures and the justification for using vaccine responses as a measure of immunotoxicity. One reviewer commented specifically “… a clearer characterization of the effect of multiple correlated PFAS on the immunosuppression attributed to PFDA is needed … The pros (and cons) of multiple confounder adjustment/potential for overfitting are all issues that should be explicitly addressed in the write up as part of the summary judgment. A more explicit discussion of the strengths, for example, of looking at titers of multiple vaccine endpoints in more than one cohort are needed as well as a discussion of how relatively small changes in titer levels at the measurement timepoints are justifiable as key endpoints.”

EPA Response: Revised text in Section 3.2.2 provides additional clarity on potential confounding by other PFAS:

"It is plausible that the observed associations with PFDA exposure could be partially explained by confounding across the PFAS or cumulative effects, although several analyses and observations indicate that this is unlikely. Exposure levels to other PFAS in the Faroe Islands populations were considerably higher (PFOS 17 ng/mL, PFOA 4 ng/mL, PFNA 1 ng/mL, PFDA 0.3 ng/mL at age 5 years in Grandjean et al. (2012), and there was a high correlation between PFDA and PFNA (r = 0.78) and moderate correlations with PFOS and PFOA (r = 0.39 and 0.35, respectively). The authors assessed the possibility of confounding in a follow-up paper (Budtz-Jørgensen and Grandjean, 2018a) that reanalyzed data from both Grandjean et al. (2012) and (Grandjean et al. 2017) for benchmark analysis. In this reanalysis, effect estimates for PFDA were adjusted for PFOS and PFOA. Details of the analytic results were provided to EPA by the authors (Budtz-Jørgensen and Grandjean, 2018b). There was variable attenuation of the observed effect estimates across the different analyses, and PFNA (the PFAS with the strongest correlation with PFDA) was not adjusted for in these models. However, details of the regression modeling results (Budtz-Jørgensen and Grandjean, 2018b) show that PFNA was a nonsignificant predictor of either tetanus or diphtheria antibody concentrations with associations just 15% the strength of the PFDA association and thus PFNA could not have been a meaningful confounder. Further, adjustment of the PFDA association by PFOS and PFOA did not eliminate the association, so confounding by co-occurring PFAS is unlikely to fully explain the associations. The details of the effects of PFDA with, and without, control of PFOS and PFOA are shown in Appendix C.1.1 with discussion of the impact and implications of multiple confounder control. Overall, while it is not possible to rule out confounding across PFAS, the available evidence suggests that it is unlikely to explain the observed effects. Other sources of potential confounding, including possible coexposures such as PCBs, were controlled appropriately. However, Grandjean et al. (2012) showed the correlation of PCBs with PFDA in their Table 2 at age 5 years as r = 0.14; the low correlation with PFDA means that PCBs could not have been a meaningful confounder of the PFDA effect estimate.”

These studies describing children's effects of PFDA on antibody concentrations were based on two birth cohorts using two types of antibodies and multiple exposure windows. Changes in titer levels in young children can be a key endpoint. Reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). Regarding the last part of the comment on the need for “a discussion of how relatively small changes in titer levels at the measurement timepoints are justifiable as key endpoints, " it is not clear to EPA if this refers to the magnitude of the observed change in tetanus antibodies of −22.3% (−35.8% to −5.8%) per twofold increase in concentrations of PFDA in 5-year olds serum ((Grandjean et al., 2012); see Table 3) which is not a small change in titer levels, or if this refers to the size of the BMR (½ SD) used in the derivation of the BMDL. Note that Appendix C.1 shows that the SD of the log_2_(tetanus antibody concentration in IU/mL) is 2.09 log_2_(IU/mL) and thus ½ SD is 1.05 log_2_(IU/mL). Exponentiating this back to the natural scale, ½-SD change in log_2_(IU/mL) is equivalent to a 2.07 IU/mL change (i.e., 2^1.05)^. The interquartile range of PFDA in 5-year-olds serum was (0.65 IU/mL, 4.60 IU/mL), so a change of 2.07 IU/mL is approximately equal to a 25% change in the distribution which is also not a small change in titer levels.

Comment: In regard to the human evidence, a reviewer noted “What is also missing from this write up is a clear statement on why the findings from the Faroe Islands cohorts, which have several unique characteristics and dietary habits, are generalizable to the United States.”

EPA Response: Similar immune suppression results have been reported in populations outside the Faroe Islands, which supports that they are relevant to U.S. populations (see Section 3.2.2; additional studies are available for other PFAS). Further, unless there is a clear explanation for why a population is not relevant to the United States (e.g., a genetic polymorphism unique to that population), relevance is assumed in order to ensure protection for vulnerable and susceptible groups. In the case of dietary habits, while diet in the Faroe Islands may be different than most of the general population in the United States, there is potential for similar high risk dietary habits within the United States

Comment: A reviewer provided the following recommendations on the presentation and synthesis of the human immune studies: 1) clarify the number and quality of studies on immunostimulation and autoimmunity to explain why these outcomes were excluded; 2) include the dichotomous titer outcome from Timmerman et al. (2021) in Table 3-12 [Table 3-11 in the revised Toxicological Review]; 3) display the results from final dataset used for the derivation of the reference dose for immune effects in Table 3-12 and clarify any differences in units; 4) state that vaccine immune titer is a functional measure of adaptive immune response and therefore an important indicator of clinically relevant immunotoxicity.

EPA Response: (1) Regarding the studies of immunostimulation and autoimmunity, please see Appendix I for the list of studies identified after public release of the draft (Qu et al., 2022; Gaylord et al., 2020; Ammitzbøll et al., 2019). Rationale for not incorporating these studies is provided there. In brief, these outcomes were not excluded from consideration in the assessment but were not discussed in the Toxicological Review due to a lack of studies in the original search; studies identified in subsequent searches were not influential on assessment conclusions due to lack of association in the small number of available studies. (2) and (3) The dichotomous titer results were not included in the table because the results in the table are expressed as percent change in antibodies. The dichotomous results are described in the text. (4) The suggested text on vaccine titer as a functional measure of adaptive immune response has been included in the section.

Comment: A reviewer recommended “EPA should reevaluate the adversity of these presumed antibody level effects, including the association with PFDA itself, and do so within the context of potential confounding [including co-exposures to other PFAS], other limitations [e.g., weak/non-statistically significant associations], and available human/animal data on disease incidence (Tier 1 necessary revision), as this has important implications for the hazard judgment and the strength of human evidence descriptor for immunosuppression (listed as ‘moderate’ in Table 3-19 [Table 3-18 in the revised Toxicological Review]).”

EPA Response: Revised text from Section 3.2.2 provides additional clarity on potential confounding by other PFAS (see response above for more details). There has been ongoing debate regarding the biological significance of small changes in serum antibody levels (DeWitt et al., 2016; IPCS, 2012; Agarwal and Cunningham-Rundles, 2007; Luster et al., 2005), but EPA's interpretation was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c) as well as by the majority of reviewers of this Toxicological Review (seven out of nine) Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism's ability to respond to an additional environmental challenge” (italics added) (U.S. EPA. 2002). Reduced antibody titers are thus considered an appropriate effect for the derivation of a candidate RfD.

Appendix C.1 provides analyses and explanations regarding the potential for confounding and confidence judgments on the resulting PODs based on the uncertainty in the POD that might be attributable to potential confounding.

Comment: The same reviewer disagreed with the evidence integration judgment for immune effects stating, “Table 3-19 [Table 3-18 in the revised Toxicological Review] indicates that human data provide ‘moderate' evidence and that ‘the inconsistent and low confidence evidence on infectious disease did not influence this judgment.' However, this points to the fact that EPA has not duly considered the implications of the null findings on human and laboratory animal infectious disease and other relevant considerations (e.g., some discussed above) for the scientific WOE, which is not a scientifically supportable approach as it does not consider all relevant data, directly relevant human data in particular. EPA should consider such null findings (and other relevant considerations) in their WOE (Tier 1 necessary revision). Combined with the 'slighť human data for sensitization and allergic response, the 'slighť laboratory animal data for immunosuppression, and the 'indeterminate' animal data for sensitization and allergic response (Table 3-19) [Table 3-18 in the revised Toxicological Review], it does not appear that PFDA exposure is ‘likely to cause' adverse immune effects in humans is sufficiently supported. EPA should reevaluate this determination (Tier 1 necessary revision) as ‘may cause' might very well be the better supported hazard judgement.”

EPA Response: The judgment that PFDA exposure is likely to cause adverse immune effects in humans was supported by the majority of reviewers of this Toxicological Review (seven out of nine). The conclusion was primarily driven by consistent evidence of reduced antibody responses across two birth cohort studies with supportive evidence of possible immunosuppressive effects in animals and limited mechanistic studies. The organization of the analyses of immune effects into different categories of immune dysfunction follows the WHO/IPCS guidance on the evaluation of immunotoxicity, an approach repeatedly supported by external reviewers. Text has been added to the evidence synthesis and integration sections describing why the infectious disease evidence does not reduce certainty in the vaccine response data. Specifically, the infection disease studies are expected to be biased toward the null due to the difficulty in measuring infectious disease and reduced study sensitivity. Similarly, the human evidence for hypersensitive-related outcomes had poor sensitivity and a small number of studies and lacked support from animal evidence. Therefore, the finding was interpreted as less certain; however, they do not influence or reduce confidence in the vaccine response data since immunosuppression and sensitization and allergic responses are considered different forms of immunotoxicity with distinct mechanisms and considerations for risk assessment according to the immunotoxicity guidelines from the WHO/IPCS (IPCS, 2012) and as described in the methodological section for immune effects (see Section 3.2.2).

#### Tier 2 Suggested Revisions

Comment: A reviewer suggested “Table 3-12 [Table 3-11 in the revised Toxicological Review]: Recommend also including a figure showing effect estimates and 95% confidence intervals, ranked by confidence level.”

EPA Response: EPA believes a table is more appropriate for this set of studies as different transformations were used in the studies, leaving the quantitative estimates not directly comparable (e.g., may represent a doubling of exposure or a in-unit increase). Given that all but one of the studies in the table are medium confidence, sorting by confidence level is not necessary.

Comment: A reviewer suggested, “EPA should consider additional tables and/or figures that would help readers visualize important EPA conclusions, such as ‘coherent evidence of potential immunosuppression in rats and mice at doses ≥0.089 mg/kg-d across two high/medium confidence studies' cited in Table 3-19 [Table 3-18 in the revised Toxicological Review].”

EPA Response: An interactive HAWC visual summarizing coherent immune responses in PFDA-exposed animals is now cited in the evidence integration section for immune effects in Section 3.2.2 and in Table 3-18.

Comment: A reviewer suggested, “Some indication if the suspected effects on the immune system were in line with data from other PFOA [PFAS] would be helpful.”

EPA Response: The evidence integration section under immune effects (see Section 3.2.2) discusses immune hazard conclusions for PFOS and PFOA, stating “Overall, the evidence [for PFDA] supports an association with immunosuppressive-type effects. These results are consistent with hazard identification conclusions from the NTP (2016) monograph on immunotoxicity associated with exposure to PFOS and PFOA, which concluded that PFOS and PFOA are presumed to be an immune hazard to humans based largely on evidence of suppression of antibody responses in both human and animal studies (NTP, 2016). Additionally, the conclusions from the Science Advisory Board (SAB) report, Review of EPA's Analyses to Support EPA’s National Primary Drinking Water Rulemaking for PFAS, are now discussed in the integration section for immune effects. The SAB panel agreed with EPA that the human evidence for PFOS and PFOA showed consistent associations between exposure and reduced antibody responses in children indicative of potential immunosuppression (U.S. EPA, 2022c). The SAB panel stated that “Decreased antibody responses to vaccines is relevant to clinical health outcomes and likely to be predictive of risk of disease. The conclusion that suppression of vaccine responses is an adverse finding is widely accepted in the field of immunotoxicology…Moreover, the immunosuppression indicated by the observed antibody decreases are not limited to those specific antigens (e.g., tetanus and diphtheria only), but rather are indicative of modulation of the general immune response.” Additionally, the SAB panel concluded that “decreased antibody responses to vaccinations are adverse effects, and that this effect is an appropriate critical effect for deriving RfDs for PFOA and PFOS.”

Comment: Two reviewers made specific suggestions regarding the issue of PFAS mixtures. One reviewer mentioned, “Although it is the goal of this assessment to develop an RfD for PFDA as if it is the only chemical causing an effect, mixture risk analysis procedures are being developed to explain the combined effect of more than one chemical exposure. The Agency may choose to strengthen their argument about PFDA using some of this logic.” The second reviewer added, “A more rigorous methodology [e.g., direct experimentation with a similar mixture, either in vivo or in vitro] is required to examine the potencies of PFAS for specific endpoints. Statistics should be supported by biological plausibility.”

EPA Response: This assessment is specific to PFDA and its related salts and the consideration of a potential additive effect of exposure to multiple PFAS chemicals would be out of scope for the current IRIS assessment. The consideration of potential additive effects of exposure to multiple PFAS could be part of subsequent risk assessment and risk management activities addressing human exposure to multiple PFAS. The draft human health toxicity values for PFDA are part of a broader PFAS strategic roadmap (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021–2024) at EPA for protecting human health and the environment from PFAS contamination. Text was added to the Executive Summary of the Toxicological Review draft to provide examples from the PFAS strategic roadmap aimed at evaluating health effects from individual PFAS and PFAS mixtures or groups. Additionally, Table 4-1 in Section 4.1 of the Toxicology Review compares health effects for PFDA and other PFAS across EPA human health assessments, highlighting notable data gaps for PFDA and PFAS in general.

### H.2.4 Public Comments on Immune Effects

Comment: One commenter agreed with EPA's conclusion that reduced antibody responses are indicative of immunosuppression and may indicate increased susceptibility to infectious disease in general. This commenter also agreed with the conclusions regarding an association between PFDA and decreased antibody responses in children based on the available epidemiological data. Conversely, two commenters raised concerns regarding the interpretation of the epidemiological data for PFDA and immunotoxicity, noting that: 1) the evidence for immunomodulation of PFAS in humans and animals is “at best 'suggestive' of an association but…too weak to draw a solid conclusion" (reviewed by Antoniou et al., [2022]); 2) lack of studies supporting the clinical relevance of reduced antibody responses and the clinically relevant impacts of PFDA exposure on reduced antibody responses; and 3) absence of accounting for likely confounding factors such as exposure to methylmercury and polychlorinated biphenyls (PCBs), which have been found to be elevated in the diet of the studied, Faroe Islands population.

EPA Response: There has been ongoing debate about the biological significance of small changes in antibody levels following vaccination, but EPA's interpretation that the changes are adverse was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (EPA 2022) and by the majority of peer reviewers for this Toxicological Review (seven of nine reviewers). Immunomodulatory effects observed in children may be broadly indicative of developmental immunosuppression impacting these children's ability to protect against a range of immune hazards.

With regard to confounding by coexposures such as PCBs, this was considered as part of the study evaluation process. The studies in the Faroe Islands considered the potential for confounding by PCBs. They reported that there were only weak correlations between PFAS and PCBs exposure (0.14 for PFDA at age 5 years), and that associations did not materially change with adjustment for PCBs. Thus, confounding by PCBs exposure was not considered likely to significantly bias the effect estimates.

### H.2.5 External Peer-Review Comments on Developmental Effects

#### Peer-Review Comment Summary

In reference to charge question 2c, the majority of peer reviewers agreed with EPA's evidence integration judgment. Three reviewers agreed with what EPA had written in this section and had no suggested Tier 1 or 2 revisions. Five reviewers agreed with EPA's conclusions but provided Tier 1 and 2 comments to strengthen those conclusions (see below). One reviewer agreed with EPA's conclusion of slight evidence for developmental effects in human studies and on that basis recommended that EPA use the Harris and Birnbaum (1989) mouse study to develop RfDs rather than a single epidemiology study (see also charge questions 3 and 4).

#### Tier 1 Necessary Revisions

Comment: A reviewer stated that on “Page 156, line 24: The sentence starting with 'Although' discussing potential bias needs to be rewritten for clarity as it is unclear what it means.”

EPA Response: The text was edited as follows: “The degree of consistency across the observational epidemiological studies varied depending on the developmental endpoints examined, with more mixed findings for non-BWT measures. In addition, the evidence of inverse associations between PFDA exposure and birth weight and birth length was less compelling when based on early or prepregnancy measures of PFDA. This might be indicative of potential bias due to the impact of pregnancy hemodynamics on PFDA levels. Thus, despite the reasonably consistent evidence of an association between PFDA and different BWT-related measures, and more mixed findings for some other endpoints, there is considerable uncertainty given that sample timing differences may explain at least some of the reported fetal growth restriction deficits.”

Comment: A reviewer stated that EPA should include a new study from Padula et al. 2023 that reported a significant inverse association for PFDA with birthweight.

EPA Response: EPA has reviewed the Padula et al. (2023) study and determined that its inclusion is not necessary given the overlap of this pooled analysis with data from populations examined in other ECHO cohort studies (Chang et al., 2022; Eick et al., 2020; Sagiv et al., 2018; Starling et al., 2017). Thus, the results were not anticipated to influence the judgments for either gestational duration or fetal growth restriction. For transparency, this characterization and rationale have been added to the Appendix I table describing the studies identified after release of the draft for public comment (see Table I-1 of Appendix I). We have also highlighted the Padula et al. study and noted the other overlapping ECHO cohort studies considered in a footnote in Table 3-19.

Comment: A reviewer stated that “Bach et al. (2016) did not log transform maternal PFDA serum levels in the continuous analysis, therefore the confidence rating in that analysis should be reduced or excluded.”

EPA Response: EPA does not automatically downgrade a study especially given more recent thinking that cautions against automatically transforming exposure data due to skewness (Choi et al., 2022).

Comment: A reviewer stated that EPA “Should note that gestational age adjusted birth weight is the preferred measure for the birth weight outcome, and indicate which studies utilized that approach.”

EPA Response: EPA could find no consensus reference on whether gestational age adjusted birth weight is the preferred measure of fetal growth restriction; this is due in part to documented concern over whether adjusting for gestational age may be a causal intermediate (Ananth and Schisterman, 2017). Given that [underlined: term births] represent a more etiologically homogeneous population, studies that restricted to term births only were considered more directly interpretable to estimate potential impacts on birth weight.

Comment: A reviewer stated that “Pubertal development is one of the four endpoints of developmental toxicity and should be discussed in this section.”

EPA Response: The developmental toxicity synthesis is focused on a narrower etiological window for early childhood effects (e.g., within the first 2 years of life for epidemiological studies) Given that the reproductive system is further differentiated later in childhood, EPA evaluated and grouped evidence on pubertal endpoints with other reproductive endpoints. Thus, the available epidemiological data for pubertal development are discussed in the sections on male (see Section 3.2.4) and female (see Section 3.2.5) reproductive effects. On a related note, text from the Toxicological Review's synthesis of developmental effects indicates that “pubertal development is discussed in the reproductive sections (see Sections 3.2.4 and 3.2.5).”

Comment: A reviewer stated that “Given the multiple possible windows of exposure for this outcome [birth weight], I recommend stating when possible whether the individual study evaluated and conclusions drawn were concerning maternal and/or neonatal PFDA exposure, especially in the Table 3-24 [Table 3-23 in the revised Toxicological Review] summary of the weight of evidence.”

EPA Response: EPA agrees that differentiating and highlighting differences across etiological windows, especially given the noted challenges with different sampling times for the exposure biomarkers, is essential to clarify the overall weight of evidence. Table 3-23 highlights this uncertainty in the “Factors that decrease strength" column, including descriptions of the sets of studies with the differing exposure biomarkers (which are delineated in greater detail by study in the evidence synthesis section): “Substantial uncertainty due to the potential impact of hemodynamic changes among studies showing birth weight deficits, especially based on late biomarker sampling defined at trimester 2 or later, e.g., 9 of 11 studies in the overall population and 6 of 9 studies in girls and 5 of 9 in boys.” The revised Toxicological Review has also extended this evaluation of early versus late sampling timing to all developmental endpoints and these results are found in the summary statements for each individual endpoint.

Comment: A reviewer stated that “The argument that uncertainty around the relationship between sample timing differences and reported fetal growth restriction deficits needs to be strengthened. Is it more likely than not to be a confounding variable and what is the evidence for this opinion? If this isnť justified, then downgrading an important observation seems unwarranted.”

EPA Response: This general issue is addressed in more detail in the Appendix F and specifics regarding potential impact on the current PFDA database are addressed in several sections on developmental epidemiological effects synthesis, dose response, and evidence integration and are highlighted for other publications (Dzierlenga et al., 2020; Steenland et al., 2018). For example, as we detail: “There was a definitive pattern by sampling timing as only 2 of the 11 studies (including 2 of 9 medium/high studies) reporting BWT deficits in the overall population had early sampling biomarker measures during pregnancy. The majority of sex-specific studies reporting BWT deficits were also based on later biomarker sampling (defined here as from the second trimester exclusive onward).” “Despite reasonably consistent evidence of an association between PFDA and different BWT-related measures, and more mixed findings for other endpoints, there is considerable uncertainty given that sample timing differences may explain at least some of the reported fetal growth restriction deficits.”

#### Tier 2 Suggested Revisions

Comment: A reviewer stated that “The evidence integration section lacks coherence as its sequencing of topics and determinations could be clearer: it is easier to understand the findings by consulting Table 3-24 [Table 3-23 in the revised Toxicological Review].” The same reviewer also stated that on “Page 156, ∼line 30–35: The text starting at line 30 seems like a more appropriate place to start the evidence integration section as it identifies the main endpoints and overall confidence.”

EPA Response: It is standard IRIS practice to have the overall evidence integration judgment as the topic sentence in the opening paragraph of the evidence integration sections. Thus, while EPA has reorganized this section to offer more clarity, the starting place was not changed.

### H.2.6 Public Comments on Developmental Effects

Comment: A commenter suggested that “considerations related to lower serum PFDA levels later in pregnancy due to hemodynamic factors discussed elsewhere in the document" be mentioned on p. 3–99, lines 19–20.

EPA Response: The comment is referencing discussion of considerations for evaluating the exposure domain of individual epidemiology studies of developmental effects. Text has been added in the revised Toxicological Review to clarify: “Although not considered as a factor influencing the exposure domain rating, the potential effects of hemodynamic factors later in pregnancy affecting serum PFDA levels and the result from individual studies is separately discussed in the evidence synthesis section and Appendix F.”

Comment: A commenter suggested that the discrepancies in the mouse fetal body weight data (Harris and Birnbaum 1989) be discussed in the text section about the dose-response data from this study (p. 3–151, lines 1–9).

EPA Response: The following text was added to the developmental section as suggested: “It should be noted that the magnitude of fetal body weight changes was actually higher in the shorter duration study (GD 10–13 vs. GD 6–15) at comparable doses. For example, decreases in fetal body weight were 4% and 10% at 0.25 and 1 mg/kg-day in the shorter (GD 10–13) experiment versus 1% and 4% at 0.3 and 1 mg/kg-day in the longer (GD 6–15) experiment. Although this dose-response trend is not expected, the reductions in fetal body weight observed in both experiments are still considered to be adverse.”

Comment: One commenter stated that “Several high or medium confidence epidemiology studies of birth weight reported no association with PFDA exposure including studies limited to PFDA levels in the first trimester.” The same reviewer stated that the evidence base for developmental effects “does not support a link between PFDA and lower birth weight in humans.” EPA Response: The majority of the external review panel (seven out of nine reviewers) agreed with the scientific justification for the selection of the studies/effects used in the derivation of the developmental RfD. EPA detailed the consistency between studies by confidence levels in Table 3-24 [Table 3-23 in the revised Toxicological Review] as well as evaluation of other potential sources of heterogeneity of results in the developmental epidemiological synthesis. And, as shown in that table and in other figures (e.g., see Figure 3-28), the majority of studies show inverse associations with mean BWT and PFDA exposures. Consistency in direction and magnitude of associations is also detailed in the various developmental effect syntheses and summary sections.

### H.2.7 External Peer-Review Comments on Male Reproductive Effects

#### Peer-Review Comment Summary

In reference to charge question 2d, seven reviewers agreed with EPA's conclusions and would have liked to have longer-term data. Two of these reviewers included Tier 1 or Tier 2 comments to expand and clarify some discussions (see below). One reviewer did not comment on this topic.

#### Tier 1 Necessary Revisions

Comment: A reviewer commented, “Non-monotonicity of testosterone effects should be noted as a possible explanation for inconsistency among male reproductive endpoints in the human studies, which rarely considered such a dose response.” The reviewer added that such considerations should be discussed as part of the literature review and evidence integration.

EPA Response: The following text on possible nonmonotonicity of testosterone effects was added to the evidence synthesis for human studies (see Section 3.2.4), “Given that the inverse associations were observed only in the studies with highest exposure concentrations in the participants, it is possible that the observed inconsistency is due to nonmonotonicity of the effect of PFDA exposure on testosterone, but the data are insufficient to determine whether this is likely, so the inconsistency decreases certainty.”

Comment: In regard to the observed reductions in body weights in male rats, a reviewer noted, “While described as 'moderate' body weight changes, reductions of 21%–38% are well above those typically considered adverse (e.g., >10% in adult animals) and would be associated with doses above the maximum tolerated dose (MTD) and overt toxicity. As such, the draft assessment should further elaborate upon, explain, and/or clarify the statement cited above (Tier 1 necessary revision).”

EPA Response: The body weight reductions (21%-38%) observed in the 28-day oral gavage studies were considered direct effects of PFDA on the male reproductive system on the basis of evidence from supplemental i.p. injection studies that examined potential effects of decreased body weight on PFDA-induced male reproductive toxicity. The i.p. injection studies used pair-fed controls that were weight-matched to PFDA treatment groups and showed that only large reductions in body weight (72%) are associated with confounding effects on male reproductive endpoints. The results are consistent with EPA's Guidelines for Reproductive Toxicity Risk Assessment that note only severe effects on body weight (e.g., >50% in some rodent studies) appear to preclude interpretations regarding reproductive effects. However, EPA agrees the term “moderate" may be confusing in this instance and has deleted it.

Comment: The same reviewer recommended that EPA scientifically justify the most human relevant laboratory species for evaluation of male reproductive effects or acknowledge this as an uncertainty.

EPA Response: The text in Section 3.2.4 has been edited: “In the absence of information to the contrary and given the conserved role of androgen-dependent pathways in male reproductive functions across species (including humans), the available evidence is considered to be relevant to humans. This assumption is based on Guidelines for Reproductive Toxicity Risk Assessment (U.S. EPA, 1996).” EPA's Guidelines for Reproductive Toxicity Risk Assessment state, “An agent that produces an adverse reproductive effect in experimental animal studies is assumed to pose a potential reproductive threat to humans.” Supporting this, EPA's Review of the RfD and RfC processes (2002) document states, “Absent a clearly most-relevant species, the most sensitive mammalian species is used, that is, the species that shows toxicity at the lowest exposure level.”

Comment: A reviewer identified a new study that evaluated sperm DNA fragmentation in humans (Pan et al., 2019) and recommended “There should be cross referencing with those finding under this toxicity endpoint. Tier 1 recommendation is to ensure that this cross-referencing is done and sited as mechanistic evidence supportive of the current conclusion in this IRIS review.”

EPA Response: As stated in Section 1.2.1, EPA evaluated studies identified during the latest literature search update (through March 2023) and public comment and provided this to the peer reviewers. As part of this evaluation, EPA's disposition on whether the studies would be incorporated on the basis of their material impact on the assessment conclusions was provided. Pan et al., (2019) was included in this compilation provided to reviewers. Although this was not a new study and it had already been considered by EPA, the study was revisited given the reviewer recommendation above. The study authors reported an association with increased sperm DNA fragmentation; however, the results for semen parameters most informative for evaluating male reproductive effects (i.e., motility, concertation, and morphology) were null, inconsistent, or imprecise (nonsignificant). Therefore, the mixed findings were not clearly supportive (nor clearly inconsistent) and EPA ultimately did not incorporate the study in the Toxicological Review since it does not influence the assessment conclusions for human or mechanistic evidence or the overall hazard judgment for male reproductive effects. Text was added to Table 1-1 in Appendix I to clarify EPA's disposition on the DNA fragmentation findings from the Pan et al., (2019) study.

#### Tier 2 Suggested Revisions

Reviewers had no tier 2 revisions.

### H.2.8 Public Comments on Male Reproductive Effects

No public comments were provided.

### H.2.9 External Peer-Review Comments on Female Reproductive Effects

#### Peer-Review Comment Summary

In reference to charge question 2e, eight reviewers agreed with EPA's weight-of-evidence conclusion for PFDA-induced female reproductive and would have liked longer-term data and more mechanistic studies whereas a lone reviewer stated that the conclusion “may be too strong given the sparse data of the single rat study" (Tier 2). Of the eight reviewers who agreed, two provided Tier 1 and 2 comments for further justification and clarity. For example, one reviewer stated that “The lactation duration outcome should be included in this section, as the pregnancy and postpartum period is a sensitive developmental window for mammary gland development.” Tier 1 Recommendations and Tier 2 Suggestions are provided below.

#### Tier 1 Necessary Revisions

Comment: A reviewer stated that “Figure 3-53: It is unclear which are male, and which are female, these should be labeled.”

EPA Response: The labels on the forest plot have been added.

Comment: A reviewer stated that “The lactation duration outcome should be included in this section, as the pregnancy and postpartum period is a sensitive developmental window for mammary gland development (as is in utero/early life). It should also be noted that mammary gland development is a sensitive outcome for other PFAS (e.g., PFOA).” The reviewer also provided citations for two epidemiolocal studies (Timmerman et al. 2017 and Romano et al. 2016) that reported associations between PFAS exposure and lactation duration as examples.

EPA Response: The studies on breastfeeding duration have been added to the Toxicological Review (see Section 3.2.5). The following statement regarding mammary gland development can be found in Section 4: “Further, the absence of studies examining the potential for effects of PFDA exposure on the thyroid in developing organisms, or on mammary glands, represent data gaps in light of associations observed for other PFAS, such as PFBS, PFOS, and PFOA (ATSDR, 2018; U.S. EPA, 2018).”

Comment: A reviewer stated that “The discussion and evidence stream (Table 3-29) should be revised to reflect the following points:

"The statement of‘unclear biological relevance of increases' in testosterone in the single (high confidence) animal study (NTP 2018) should be revised to note coherence with the finding of continuous diestrous as high levels of androgens in women causes infrequent, irregular, or non-existent menstruation.

The finding of high testosterone and a continuous phase of diestrous in the (NTP, 2018) study is also consistent with the finding of decreased progesterone in Leydig tumor cells (Zhao et al., 2017). High levels of testosterone in women are associated with levels of progesterone, irregular menstruation, and decreased fertility.”

EPA Response: EPA responds to these comments as follows:

1. Text was added to Section 3.2.5 to highlight the possible coherence between increased testosterone levels and prolonged diestrus observed in PFDA-treated rats from the NTP 2018 study. The following text was added to the section on hormone levels: “studies have shown that high levels of androgens (e.g., testosterone) can cause irregular menstruation cycles in women. For example, Van Anders and Watson (2006) reported an association between high levels of testosterone and increased menstrual cycle length in healthy premenopausal women. Such findings could suggest possible coherence between increased testosterone levels and prolonged diestrus observed in PFDA-treated female rats from the (NTP, 2018) study given that the mechanisms responsible for regulating female reproductivity (e.g., estrous cyclicity in rats and menstrual cycling in humans) are similar between rats and humans (Goldman et al., 2007; Bretveld et al., 2006).” Subsequently, corresponding text was added to the evidence profile table for female reproductive effects.
2. As stated in Table 3-29, the evidence of PFDA-decreased progesterone production in mouse Leydig tumor cells ([underlined: Zhao etal., 2017]) cannot be corroborated with data from the lone reproductive study in rats (NTP, 2018). given that progesterone levels were not measured in the 2018 NTP study. Furthermore, the available scientific literature for links between progesterone and testosterone do not seem to provide support for the PFDA-induced effects on the female reproductive system. For example, decreased progesterone levels may actually lead to low testosterone given that progesterone is a precursor to the production of testosterone. Additionally, testosterone was shown to increase progesterone production under in vitro conditions (Rangel et al., 2007). Therefore, this recommendation was not incorporated into the Toxicological Review.

Comment: A reviewer asked for more clarification regarding the following statement:

"Although decreased body weight in female rats was observed at the same doses (body weight decreases were 12%-36% at ≥1.25 mg/kg-day; refer to Section 3.2.10 on General toxicity effects for more details) as effects on estrous cyclicity, it is unclear if these effects are related and the effect on female reproductive function is disproportionately more severe and concerning than the moderate changes in body weight.” The body weight changes are described as “moderate" but reductions of 21%-38% are well above those typically considered adverse (>10% in adult animals).

EPA Response: It is noted that the EPA reproductive toxicity guidelines discuss body weight changes using the terms “mild, " “moderate, " and “severe, " citing evidence that only “severe" effects on body weight (e.g., >50% in some rodent studies) appear to preclude interpretations regarding reproductive effects. It is also noted that a 10% change in body weight is not necessarily a cutoff for adversity, although it can be and has been used as an appropriate BMR (or minimally adverse change), depending on the study- and evidence-specific decision context. However, EPA agrees the term is confusing in this instance and thus deleted “moderate.”

Comment: The same reviewer also asked for more clarification regarding the following statement: “Although body weight has been shown to fluctuate during the different estrous stages and weight loss has been shown to correlate with disrupted estrous cyclicity in rats (Tropp and Markus, 2001), it is not possible to determine if the decreases in body weight in female rats might be responsible for the effects on estrous cyclicity observed in the NTP (2018) study. Furthermore, even though no changes were observed on other stages of the estrous cycle (i.e., proestrus and metestrus), the effects of PFDA on estrus and diestrus are still considered biologically relevant given the potential influence that the lack of cyclicity may have on fertility, regardless of whether the observed decrease in body weight may have partially contributed to these changes.” The reviewer further stated that “EPA should clarify how it was determined that decreases in body weight only ‘may have partially contributed' to estrous cycle effects given the statement [emphasis added] that ‘it is not possible to determine if the decreases in body weight in female rats might be responsible for the effects on estrous cyclicity observed.'"

EPA Response: As the reviewer points out above, the Toxicological Review indicates the PFDA-induced effects on estrous cyclicity are disproportionately more severe than changes in body weight. For example, the percentage of time spent in diestrus was statistically significantly increased by 27–63% at ≥1.25 mg/kg-day compared with 12%-36% decreases in body weight at the same doses. Given the PFDA-induced estrous effects are more severe than body weight changes, these data, at a minimum, are interpreted to indicate the effects on diestrus and estrus are not entirely due to decreased body weight. Furthermore, without time-course data showing effects on estrous cyclicity and body weight at multiple intervals, it is not possible to make definitive conclusions on the possible contribution of PFDA-induced body weight changes on estrous cyclicity effects.

Comment: The same reviewer commented that EPA should scientifically justify the rat as the most human relevant laboratory animal species for female reproductive effects or acknowledge this as an uncertainty.

EPA Response: The following text has been added to Section 3.2.5: “These findings are interpreted as relevant to humans in the absence of evidence to the contrary. This assumption is based on Guidelines for Reproductive Toxicity Risk Assessment (U.S. EPA, 1996).” As stated in EPA's review of the RfD and RfC processes (2002) document, “Absent a clearly most-relevant species, the most sensitive mammalian species is used, that is, the species that shows toxicity at the lowest exposure level.” Furthermore, EPA's Guidelines for Reproductive Toxicity Risk Assessment states that “An agent that produces an adverse reproductive effect in experimental animal studies is assumed to pose a potential reproductive threat to humans.” In the case of PFDA, no data were identified to suggest the rat data from the NTP 2018 study would not be relevant to humans.

#### Tier 2 Suggested Revisions

Comment: A reviewer stated that EPA “Should note that while the histopathology study found no effects on the mammary glands, timing of the exposure and outcome was not in a sensitive developmental window (in utero or pregnancy).”

EPA Response: The text in the evidence integration discussion of Section 3.2.5 has been edited as follows: “Given the short-term duration of the lone animal study, it cannot be reasonably ruled out that detectable histopathological effects could have become apparent with a longer study duration or during a sensitive developmental window (e.g., in utero or pregnancy).”

Comment: A reviewer stated that the hazard conclusion for female reproductive effects may be too strong given the sparse data of the single rat study and should be reconsidered.

EPA Response: The hazard conclusion for PFDA-induced female reproductive effects is based on considerations outlined in the IRIS Handbook where a single well-conducted study can be used to support an evidence synthesis conclusion of "moderate" and an evidence integration conclusion of "evidence indicates (likely).” In addition, this conclusion was supported by eight of the nine peer reviewers.

### H.2.10 Public Comments on Female Reproductive Effects

No public comments were provided.

### H.2.11 External Peer-Review Comments on Cardiometabolic Effects

#### Peer-Review Comment Summary

In reference to charge question 2f, all nine reviewers agreed with EPA's conclusions. Two reviewers provided Tier 2 suggestions for improvement (see below).

#### Tier 1 Necessary Revisions

Reviewers had no Tier 1 revisions.

#### Tier 2 Suggested Revisions

Comment: While in agreement with EPA's conclusions, a reviewer provided the following comment, “The justification of [cardiometabolic effects] would be more coherent if there was a logic tree that walked the reader through the various pathways by which PFDA affects each examined contributor to overall cardiometabolic health.” Similarly, another reviewer suggested, “It would be useful to include some background on why this was evaluated based on MOA.”

EPA Response: Given the limited nature of the evidence for cardiometabolic effects, it is not possible to accurately characterize the pathways as suggested without additional scientific study. The agreed-with conclusion of slight human evidence and suggestive evidence overall is intended to highlight the need for such additional research and thus, no additional MOA analysis or pathway examination was added.

Comment: A reviewer noted, “The clinical relevance of Tables 3-30, 3-33, and 3-34 could be made easier to interpret if the various measurement units for the various relevant outcomes (such the lipid subfractions, fasting blood glucose, and waist circumference, respectively) were provided for the studies that reported the ß effect estimate (Tier 2 Recommendation).” This reviewer added “It would be additionally helpful in Section 3.2.6 to provide more details of the lipid subfractions reported in the studies (e.g., the strength and directionality of association between PFDA exposure and not just total cholesterol levels, but also LDL, HDL, and triglycerides, since HDL elevation is protective while elevation of the other subfractions are adverse outcomes); similarly, the evidence integration section can be better clarified in this regard [Tier 2 Recommendation]).”

EPA Response: Units for the outcome measures were added to Tables 3-30, 3-33, and 3-34. Results are presented for LDL and triglycerides in Table 3-30 and discussed in text. Data for HDL were also reviewed to determine whether they would influence assessment conclusions and were determined not influential to the assessment conclusions.

### H.2.12 Public Comments on Cardiometabolic Effects

No public comments were provided.

### H.2.13 External Peer-Review Comments on Neurodevelopmental Effects

#### Peer-Review Comment Summary

In reference to charge question 2g, all reviewers agreed with EPA's conclusions. Two reviewers provided Tier 2 suggestions (see below).

#### Tier 1 Necessary Revisions

Reviewers provided no Tier 1 revisions.

#### Tier 2 Suggested Revisions

Comment: A reviewer suggested “Table 3-38 can be strengthened if it has more information on participants ages/age categories and breaking out results by gender as feasible when clinically relevant (e.g., ADHD tends to be more often diagnosed in boys vs. girls).”

EPA Response: Additional detail has been added to the table on sex and age. None of the studies presented sex-stratified results, so results broken out by gender is not possible, but each of the studies either matched for sex or adjusted for it. Those that did not match did additionally examine potential interaction by sex but there was no clear indication of a difference in response by sex.

Comment: Another reviewer asked for clarification (with one or two sentences) on the availability of any supportive evidence such as coherence with mechanistic data (e.g., CompTox data) or animal data and a reference to possible consistency with other long-chain PFAS.

EPA Response: As described in Section 3.2.7, the database for PFDA-induced neurodevelopmental effects is limited to a few human studies that showed inconsistent results and no data in animals via any relevant route and duration. Given these uncertainties and the overall paucity of mechanistic data available to inform this health outcome, EPA did not perform a comprehensive evaluation of mechanistic data or supplemental information from other PFAS since it would not change the assessment conclusions or help address key data gaps.

### H.2.14 Public Comments on Neurodevelopmental Effects

No public comments were provided.

### H.2.15 External Peer-Review Comments on Endocrine, Urinary and Other Noncancer Effects

#### Peer-Review Comment Summary

In reference to charge question 2h, five reviewers agreed with EPA's conclusions for endocrine (i.e., thyroid), urinary, and other noncancer effects, whereas two reviewers agreed with the conclusions for only urinary and other noncancer effects. Three reviewers disagreed with EPA's conclusions for endocrine effects, with two reviewers providing Tier 1 comments questioning EPA's interpretations regarding potential thyroid toxicity (see below). One reviewer did not explicitly state whether they agreed with EPA's conclusion for endocrine effects but did provide Tier 1 and Tier 2 comments (see below).

#### Tier 1 Necessary Revisions

Comment: A reviewer stated that EPA should clarify that the conclusions of inadequate evidence for endocrine effects do not apply for reproductive hormones (male and female reproduction), which are also part of the endocrine system.

EPA Response: The following text was added to Section 3.2.8: “Potential PFDA effects on male and female reproductive organs (e.g., testes and ovaries) and reproductive hormones (e.g., testosterone) that also encompass part of the endocrine system are discussed in the sections on male reproductive effects (Section 3.2.4) and female reproductive effects (Section 3.2.5.”

Comment: A reviewer stated that EPA should reexamine the evaluation of epidemiological studies for thyroid effects for consistency in the interpretation of pathway responses from other IRIS Toxicological Reviews on related PFAS (e.g., PFHxA). Several factors that were used to identify studies as “deficient" are concerning, such as only studies with fasting thyroid measurements being deemed nondeficient and considering studies that did not take thyroid measures at the same time of day for all measurements deficient. Another concerning factor is the difference in interpretation of the human studies for PFDA versus other PFAS that found consistent effects for thyroid hormones that were not always associated with changes in TSH. This reviewer thought the designation for the human evidence for PFDA would be slight or higher on the basis of these considerations.

A second reviewer echoed the concerns about deficiencies identified by EPA on the basis of how thyroid measurements were taken, stating “In the methodological considerations of the endocrine studies, serum thyroid hormone concentrations are not usually regarded to have diurnal variation, and this may have thus been an unnecessary limitation" and “to not regard thyroid-related studies that failed to consider diurnal variation as deficient.”

EPA Response: The text in the Toxicological Review has been revised to emphasize that lack of consideration of fasting or diurnal variation was not considered a major source of bias and that studies were not downgraded in overall study confidence if this was the primary limitation identified (i.e., such a limitation led to a rating of "deficient" only within the outcome domain, but this limitation alone did not decrease the potential influence of these studies on the evidence synthesis judgment as such studies were medium confidence overall, as shown in Figure 3-79; the outcome domain is the third column).

The statement about lack of coherence across thyroid measures has been removed.

Regarding the judgment of slight versus indeterminate, EPA feels the conclusion of indeterminate is justified because the majority of studies are null. There is a concern for reduced sensitivity due to limited exposure contrast in most of the studies, which reduces our ability to interpret null results (i.e., they are not interpreted as evidence of no effect given this limitation), however, there is not sufficient evidence to reach slight or higher at this time. A table of results has been added to the synthesis, which may make it easier for readers to get an understanding of the existing evidence.

Comment: The same reviewer also stated that EPA should reexamine the animal studies for thyroid effects as the designation of “lack of expected coherence across thyroid measures with any currently available understanding of adverse thyroid-related change" does not appear consistent with conclusions or observations for other PFAS. The reviewer suggested that an evidence stream judgment of "moderate" would be more appropriate based on the in vivo animal data.

EPA Response: It is important to note that the PFDA database for thyroid effects is more limited in the number of studies and less consistent when compared with other PFAS. For example, PFBS exposure was shown to decrease total T3, total T4, and free T4 in pregnant mice, nonpregnant adult male and female rats, and female offspring mice exposed through gestation (U.S. EPA, 2021a). Furthermore, other PFAS chemicals like PFHxA and PFHxS have been shown to cause similar effects to PFBS on the thyroid economy in rodents (decreased T3 and T4 with normal levels of TSH) (U.S. EPA, 2023b, 2021a). In the case of PFDA, effects on the thyroid economy in rodents were limited to a single study in adult rats (NTP, 2018). In the NTP 2018 study, PFDA caused a statistically significant decreasing trend in TSH in males only, a statistically significant increasing trend for T3 in male and female rats with significant increases reported at ≥1.25 mg/kg-day for females only, statistically significant decreases in free T4 in both sexes, and a lone statistically significant decrease in total T4 at the second lowest dose in males only. The lack of large or consistent decreases in total T4 and increases in T3 with PFDA exposure are key divergences from the findings for other PFAS with stronger evidence judgments; the reason for these inconsistencies requires further study. So not only are the effects of PFDA on thyroid homeostasis mixed and incoherent, but they are also not consistent with other PFAS. Further inconsistency is introduced by the mechanistic and supplementary data for PFDA. Taken together, EPA feels that the evidence synthesis of indeterminate for the endocrine effects in animals is justified for PFDA. Also as stated above, the majority of the peer-review panel (five of the nine reviewers) agreed with EPA's conclusions for endocrine effects; an additional reviewer did not explicitly state whether they agreed with EPA's conclusion for endocrine effects.

Comment: The same reviewer also stated that EPA should clarify in the animal study discussion and evidence integration table (Table 3-42 of the revised Toxicological Review) that histopathology findings would not necessarily be expected from the 28-day rat study given the short-term duration of the study. This is consistent with the observed null histopathological findings.

EPA Response: The following text was added to the evidence integration discussion of Section of 3.2.8: “Regarding the lack of PFDA-induced histopathological changes in endocrine tissues, it cannot be reasonably ruled out that detectable histopathological effects could have become apparent with a longer study duration.”

Comment: The same reviewer also stated that EPA should reevaluate the evidence integration judgment of “inadequate evidence" given the previous comments and consider a designation of “suggestive" or higher.

EPA Response: The overall summary judgment is based on the separate evidence stream judgments, in this case indeterminate for evidence in both humans and animals and with limited, inconsistent mechanistic support (comment responses on these separate judgments are provided above). Given those judgments, inadequate evidence is the appropriate combined judgment (please see the PFAS protocol and IRIS Handbook for additional details).

Comment: A reviewer stated that “Any included studies of thyroid hormone status in pregnancy should not be combined with the same assessments as non-pregnant adults, given the different reference ranges for TSH and of changes in the binding of serum thyroid hormone levels in gestation.”

EPA Response: The synthesis has been updated to separate general population adults and pregnant women.

Comment: The same reviewer also stated that “Given the multiple possible windows of PFDA exposure on thyroid effects, it would be clearer to state when possible whether the individual study evaluated, and conclusions drawn were concerning maternal and/or neonatal PFDA exposure.”

EPA Response: A table that includes the timing of exposure measurement has been added to the synthesis of human evidence.

Comment: A reviewer stated that “The Agency should incorporate the concept of ‘coherence’ in terms of the response to chemicals that do not act as a goitrogen per se.”

EPA Response: As suggested by the reviewer, EPA reviewed the available data for thyroid effects induced by nongoitrogenic chemicals (e.g., PCBs, PBDEs) to compare to PFDA effects. Goldey and Crofton (1998) reported that gestational exposure to Aroclor 1254 decreased levels of T4 in rats with no effect on T3. In adult rats, Aroclor 1254 decreased levels of T4 with no change in T3 or TSH (Hood and Klaassen, 2000). PBDE mixtures were reported to decrease levels of T4 and T3 in weanling rats with no effect on TSH (Zhou et al., 2001). In short, the effects of PCBs and PBDEs on thyroid economy do not appear to be comparable or add support to the results of PFDA, but they do exhibit results similar to those observed following exposure to PFAS other than PFDA (e.g., PFBS; PFBA; PFHxA; PFHxS). It should also be noted that EPA is not questioning the adversity of decreased T4 but rather concluding that that there is inadequate evidence to determine whether PFDA exposure might cause thyroid (or other endocrine) effects in humans. Also as stated above, the majority of the peer-review panel (five of the nine reviewers) agreed with EPA's conclusions for endocrine (i.e., thyroid) effects; an additional reviewer did not explicitly state whether they agreed with EPA's conclusion for endocrine effects.

#### Tier 2 Suggested Revisions

Comment: A reviewer stated that “Established determinations of thyroid effects for other PFASs (e.g., PFOA and PFOS) should be noted" and that the human evidence for the thyroid hormone section “would benefit from a table and/or figure grouped by confidence level and noting limitations.”

EPA Response: This information can be found in Table 4-1 (see Section 4.1) that facilitates comparisons of endocrine toxicity hazard conclusions across EPA PFAS assessments. A table of results sorted by population and study confidence has been added to the human evidence synthesis.

Comment: A reviewer stated that “Animal studies and even human studies with compounds that target the thyroid system result in outcomes that are not classic (decrease in serum T4 and increase in serum TSH). The results are often not considered or understood. It would be very useful for the EPA offices to have the same view about thyroid endpoints.”

EPA Response: EPA's conclusions for PFDA-induced endocrine effects are not inconsistent with other EPA assessments. As noted above, the PFDA database for thyroid effects is not identical, is more limited with respect to the number of studies and is less consistent when compared with other PFAS and other chemical groups like PCBs and PBDEs. For example, were the PFDA-specific studies showing effects (that were at all consistent, large, or dose-dependent) only on serum total T4, with or without changes in TSH, the assessment would make a stronger evidence synthesis judgment.

### H.2.16 Public Comments on Endocrine, Urinary, and Other Noncancer Effects

Comment: A commenter suggested “mentioning that the possible contribution of decreased food consumption to decreased body weight is unknown in some or all of these studies (e.g., NTP, 2018, and Frawley et al., 2018) because food consumption was not measured [page 3–283, lines 1–20].”

EPA Response: The suggested text was added to Section 3.2.10. Furthermore, the following text can be found in the section: “Key issues regarding study quality evaluation in the medium and low confidence studies were related to exposure sensitivity (no analytical verification methods or quantitative data on food consumption).”

## H.3 CHARGE QUESTIONS 3 AND 4 – NONCANCER TOXICITY VALUE DATA SELECTION AND MODELING

3 For PFDA, no RfC was derived for inhalation exposures. An RfD is derived based on studies by Budtz-Jørgensen and Grandjean (2018) and Grandjean et al. (2012) showing decreased serum antibody concentrations for both tetanus and diphtheria in children (male and female) at age 7 years and PFDA measured at age 5 years and developmental effects (i.e., reduced birth weight in humans) from the Wikström (2020) study. Given the close proximity of the developmental and immune PODs and resulting osRfDs and because these effects are observed during the developmental period, they are selected as co-critical effects supporting the RfD. Is the selection of the studies for the immune (Budtz-Jørgensen and Grandjean, 2018) and developmental (Wikström, 2020) effects for use in deriving the RfD values for PFDA scientifically justified? Are the modeling approaches appropriate?
  a) If so, please provide an explanation.
  b) If not, please provide an alternative study(ies) or effect(s) that should be used to support the derivation of the lifetime RfD and detail the rationale for use of such an alternative.
  c) As part of the recommendations in “a” or “b" above, please comment on whether the effects selected are appropriate for use in deriving the lifetime RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection.^8^ Please also see charge questions 2b and 2c.
  d) EPA used benchmark dose modeling (BMD) (U.S. EPA, 2012) to identify points-of-parture (PODs) for PFDA. Are the BMD modeling approaches, selection and justification of benchmark response levels, and selection of the BMD models used to identify each POD for toxicity value derivation scientifically justified and clearly described?
  e) For liver, male reproductive and female reproductive effects, quantitative information was limited to studies in animals exposed to PFDA for 28 days and little to no information was available to evaluate the effects of chronic exposure on these health hazards. Therefore, the derivation of lifetime organ-specific (os) RfD values was not attempted for liver, male reproductive and female reproductive effects. However, these endpoints were considered for the derivation of subchronic osRfDs. Does the provided scientific rationale support this decision? Please explain.
  f) Given the lack of studies on inhalation exposure to PFDA, no referenconcentration (RfC) is derived. Please comment on this decision.
4 In addition, for PFDA, an RfD for less-than-lifetime ("subchronic") exposures is derived. No subchronic RfC was derived. The same studies and outcomes were chosen for use in deriving the lifetime and subchronic RfDs. Are the selection of these studies and these effects for the derivation of the subchronic RfD for PFDA scientifically justified?
  a) If so, please provide an explanation.
  b) If not, please provide an alternative study(ies) or effect(s) that should be used to support the derivation of the subchronic RfD and detail the rationale for use of such an alternative.
  c) As part of the recommendations in “a" or “b" above, please comment on whether the effects selected are appropriate for use in deriving the subchronic RfD, including considerations regarding adversity (or appropriateness in representing an adverse change) and the scientific support for their selection.
  d) Please comment on the other subchronic osRfDs (i.e., for liver, male reproductive, and female reproductive effects).
  e) Given the lack of studies on inhalation exposure to PFDA, no subchronic RfC is derived. Please comment on this decision.

### H.3.1 External Peer-Review Comments on Noncancer Toxicity Value Data Selection and Modeling for the Lifetime ("Chronic") Reference Dose (RfD)

#### Peer-Review Comment Summary

In reference to charge question 3, the majority (seven) of reviewers agreed that selection of Budtz-Jørgensen and Grandjean (2018) and Wikström (2020) for deriving the RfD values was scientifically justified and that the modeling approaches were appropriate for immune and developmental effects, respectively. One reviewer did not comment in response to this question. Another reviewer commented that the selection of the studies was not scientifically justified and appropriate for modeling RfDs for immune and developmental effects of PFDA, and recommended modeling of alternative studies. The reviewers provided several Tier 1 and Tier 2 comments (see below) on this topic, and several Tier 3 future considerations were identified (see peer-review report).

Specifically in reference to charge question 3a, one reviewer (with concurrence expressed by three other reviewers during the meeting) commented that while the studies were reliable sources given the underlying data, EPA should comment on clinical relevance, uncertainties, and justification of the choices made in the derivation of the RfDs, and another reviewer similarly recommended that EPA add additional discussion of confounding in the selected studies (see below). A fifth reviewer added that selection of co-critical effects is reasonable given the proximity of the points of departure for the effects and that they are both observed during the developmental period.

In reference to charge question 3b, while the majority of reviewers supported EPA's decisions, one reviewer did not agree and provided several Tier 1 recommendations (see below). In general, the reviewer commented that for immune effects, Budtz-Jørgensen and Grandjean (2018) reported inconsistent and/or insignificant associations between antibody concentrations and PFDA, did not adjust for confounding from associated other PFAS, defined the “clinically protective" level of serum antibodies as a higher concentration than typical for the assay, and also noted no evidence of increased incidence of tetanus or diphtheria, despite NHANES data indicating that the U.S. population geometric mean serum level of PFDA is higher than the POD. Further, the reviewer commented that EPA did not adequately consider other immune studies with null findings. For birth weight, the reviewer commented that EPA should use a metanalysis or data from Harris and Birnbaum (1989) rather than Wikström (2020), given the weight-of-evidence designation for the epidemiological literature as slight.

In reference to charge question 3c, three reviewers agreed that the selected effects are appropriate for use in deriving the lifetime RfD, with one of the reviewers suggesting EPA increase discussion of the pharmacokinetic differences associated with pregnancy that could affect the interpretation of the epidemiological studies (see below). Most reviewers did not comment on 3c.

Specifically in reference to charge question 3d, five reviewers agreed that the BMD modeling approaches, selection and justification of BMRs, and selection of BMD models used to identify each POD for toxicity value derivation are scientifically justified and clearly described and did not provide additional comments. Two reviewers commented that while some aspects were clearly described, the issue of mixtures and confounding from other associated PFAS was not adequately addressed (see below). One reviewer did not comment on 3d. The last reviewer disagreed with EPA's approaches (see comments below). This reviewer indicated that the modeling approaches in general were scientifically justified but provided Tier 1 comments disagreeing with EPA's decisions regarding the adversity of the immune effect (decreased antibodies) and the justification EPA provided for the use of the lower BMR. This reviewer also recommended using the rodent study by Harris and Birnbaum (1989) rather than a single epidemiological study for developmental effects.

In reference to charge question 3e, six reviewers agreed with the scientific rationale to consider deriving subchronic osRfDs but not lifetime osRfDs because of the limited quantitative information, with one of the reviewers suggesting increasing the uncertainty factor range to estimate chronic osRfDs. One reviewer commented that the Kim et al. (2019) PBPK model should have been modified for PFDA to derive subchronic osRfDs. The remaining two reviewers did not comment on 3e.

#### Tier 1 Necessary Revisions

Comment: A reviewer commented on the issue of confounding from PFAS coexposures and made the following recommendation: “Expand the discussion and consideration of confounding factors (especially co-exposures to PFNA) in the context of their potential quantitative impact on the derivation of the RfD for immune and developmental effects. At a minimum clarify the rationale for evaluating the effects of PFNA co-exposures as non-significant based on the analytical details of the regression models performed by the authors of Budtz-Jørgensen and Grandjean 2018 (HERO 7276745).”

EPA Response: The text in Section 3.2.2 has been revised to provide additional clarity on potential confounding by other PFAS for immune effects, as follows:

"It is plausible that the observed associations with PFDA exposure could be partially explained by confounding across the PFAS or cumulative effects, although several analyses and observations indicate that this is unlikely. Exposure levels to other PFAS in the Faroe Islands populations were considerably higher (PFOS 17 ng/mL, PFOA 4 ng/mL, PFNA 1 ng/mL, PFDA 0.3 ng/mL at age 5 years in Grandjean et al. (2012), and there was a high correlation between PFDA and PFNA (r = 0.78) and moderate correlations with PFOS and PFOA (r = 0.39 and 0.35, respectively). The authors assessed the possibility of confounding in a follow-up paper (Budtz-Jørgensen and Grandjean, 2018a) that reanalyzed data from both Grandjean et al., (2012) and (Grandjean et al., 2017) for benchmark analysis. In this reanalysis, effect estimates for PFDA were adjusted for PFOS and PFOA. Details of the analytic results were provided to EPA by the authors (Budtz-Jørgensen and Grandjean, 2018b). There was variable attenuation of the observed effect estimates across the different analyses, and PFNA (the PFAS with the strongest correlation with PFDA) was not adjusted for in these models. However, details of the regression modeling results (Budtz-Jørgensen and Grandjean, 2018b) show that PFNA was a nonsignificant predictor of either tetanus or diphtheria antibody concentrations with associations just 15% the strength of the PFDA association and thus PFNA could not have been a meaningful confounder. Further, adjustment of the PFDA association by PFOS and PFOA did not eliminate the association, so confounding by co-occurring PFAS is unlikely to fully explain the associations. The details of the effects of PFDA with, and without, control of PFOS and PFOA are shown in Appendix C.1.1 with discussion of the impact and implications of multiple confounder control. Overall, while it is not possible to rule out confounding across PFAS, the available evidence suggests that it is unlikely to explain the observed effects. Other sources of potential confounding, including possible coexposures such as PCBs, were controlled appropriately. However, Grandjean et al. (2012) showed the correlation of PCBs with PFDA in their Table 2 at age 5 years as r = 0.14; the low correlation with PFDA means that PCBs could not have been a meaningful confounder of the PFDA effect estimate.”

Comment: In regard to the BMD modeling approach used to derive PODs from epidemiological studies, a reviewer commented “… From a toxicology perspective it appears unlikely that a molecule (PNDA[PFDA]) which represents only a few percent of a total mixture concentration in serum can be teased out for regulatory purposes. However, from an epidemiology perspective and a BMDL perspective this was accomplished. This needs to be explained in a lay [non-epidemiological] language. Provide the strengths and weaknesses of this methodology.”

EPA Response: EPA agrees that having more mixtures-based toxicological studies may shed further light on the potential contribution of individual PFAS for different endpoints. EPA has commented in various sections on the potential impact of other PFAS coexposures, including the most highly correlated and most consistent one (PFNA), and the degree that the epidemiological evidence helps elucidate the potential impact of other PFAS on PFDA responses.

In some instances, EPA can use information about the relative effects of other measured PFAS to ascertain that a weaker effect cannot substantially confound a stronger effect (see response to previous comment).

Comment: Two reviewers commented on the selection of the BMR for immune effects. One reviewer asked for more clarity, stating “The justification for using the response level is not completely clear, and should be compared with other options, e.g., a 10% BMR, so the authors can discuss and illustrate the significance of this choice.” The second reviewer disagreed with the BMR justification, indicating"… the draft assessment: (a) is not using the demonstrated severity/adversity of the effect itself (decreased antibodies) as support for the lower BMR (i.e., ½ SD); and (b) is using an admittingly unclear definition of an adverse effect (antibodies <0.1 IU/mL)^(32)^in an attempt to justify/support the lower BMR of ½ SD. (a) is problematic and (b) is internally inconsistent as the draft does not scientifically support the definition of <0.1 lU/mL as the adverse cutoff. These justifications/support for the BMR should be removed (Tier 1 necessary revision).”

EPA Response: EPA defines an “adverse effect” as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism's ability to respond to an additional environmental challenge” (U.S. EPA, 2002). Immunosuppression is a functional impairment (IPCS, 2012). Whether or not the observed immunosuppression is eventually identified with clinical studies, it is clear that fewer antibodies reduce people’s ability to respond to additional immunological challenges. Thus, EPA considers decreased antibody concentrations an appropriate endpoint for estimating an RfD. Regarding the magnitude of the benchmark response (BMR), EPA explained in Appendix C.1 that in the absence of a scientific consensus on the size of a change in antibody concentrations, the EPA technical guidance suggests the use of a 1-SD change (akin to a BMR of a 10% change), or a ½-SD change (akin to a 5% change). Thus, reviewers can compare PODs across endpoints at the ~10% or 5% BMR levels. It is noted that the practice is often to use a lower BMR (e.g., 5% or ½ SD) for effects resulting from exposure during development due to the assumption of increased susceptibility, even for similar outcomes that might warrant a higher BMR (e.g., 10% or 1 SD) if the exposure was to adults. As stated above, this practice is supported by EPA’s Benchmark Dose Technical Guidance, which states “…if warranted by statistical or biological considerations, a lower or higher increment of the control [standard deviation] might be used.” (U.S. EPA, 2012)

Comment: A reviewer questioned the decision to select BMDLs for the derivation of the reference dose for immune effects that did not control for PFOS and PFOA, noting that"… The results of Weisskopf et al. (2018) do not constitute reasonable doubt that for these PFDA results, the confounding from not adjusting for co-exposures to documented immunotoxicants (PFOS, PFOA) is significantly greater than the potential amplification of biases that remains undemonstrated under the same or similar circumstances. EPA should reevaluate the issues raised above in regard to implications for their draft PFDA assessment (Tier 1 necessary revision).”

EPA Response: Appendix C.1 provided explanations acknowledging the potential tor confounding and confidence judgments on the resulting PODs on the basis of the uncertainty in the POD that might be attributable to potential confounding. There was a statistically significant effect of PFDA in the single-PFAS model, and when PFOS and PFOA were added to the model, there was some attenuation of the point estimate (37% smaller) and the p-value lost statistical significance (p = 0.15). Given that the multi-PFAS model included three PFAS variables that were correlated with each other by about r = 0.5, loss of statistical significance is not unexpected. There was less attenuation in the lower bound of the point estimate (18%), which is used to derive the BMDL. EPA also noted that the cause of the difference in the effect estimates for PFDA could have been due to coexposure amplification bias and that it is not known which possible bias to assign the change in effect estimate to. EPA considered that the uncertainties in the precise value of the lower bound were small relative to the accepted uncertainty in the definition of the RfD itself. The BMDL for the single-PFAS model was 0.411 ng/mL in serum and the BMDL for the multi-PFAS was 0.497 ng/mL in serum. The candidate RfD value for PFDA from the single-PFAS model after conversion to POD_HED_ and application of the uncertainty factor was 2 x 10_-9_ (mg/kg-d) (see Table 5-12); had the BMDL from the multi-PFAS been advanced as a candidate RfD value, the numerical value would have been the same to within one significant figure.

The following text on potential confounding has also been added to Appendix C.1:

Additional details about other potential confounders:

- PFNA is not a significant predictor in the single-PFAS model (β = −0.227; p = 0.16) and the association is just 15% the strength of the PFDA association (Budtz-Jøgensen and Grandiean, 2018b), thus PFNA could not have been a meaningful confounder even though PFNA was highly correlated with PFDA (r = 0.78) Grandiean et al. (2012)).
- PCBs had a weak correlation with PFDA (r = 0.14; Grandiean et al. (2012)), meaning that PCBs could not have been a meaningful confounder of the PFDA effect estimate.

In addition, clarifying text has been added to the main document (see responses above).

Comment: The same reviewer reiterated disagreement with the hazard descriptor of "likely" for immune effects emphasizing the null findings on the human and laboratory animals on infectious disease (see previous comment under Section A.2.3), and asked EPA to reconsider the use of the serum antibody endpoints for quantitative risk assessment/derivation of toxicity factors. The reviewer also noted recent conclusions by the Australian government (FSANZ 2021) and the U.S. Agency for Toxic Substances and Disease Registry (ATSDR 2021) stating that associations between PFAS and immunological effects do not provide a suitable basis for quantitative risk assessment.

EPA Response: Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect" as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism's ability to respond to an additional environmental challenge" (italics added) (U.S. EPA, 2002). Reduced antibody production is thus an appropriate effect for the derivation of a candidate RfD. The majority of the external review panel (seven of nine reviewers) agreed with the scientific justification for the selection of the immune effect used in the derivation of the lifetime RfD. Furthermore, EPA’s interpretation of the immune effect was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c). Moreover, reduced antibody responses were used to support a 2016 NTP conclusion that PFOS and PFOA are presumed to be an immune hazard to humans (NTP, 2016).

Comment: A reviewer noted the following discrepancy: “Note that in the Supplemental section Table F.3 (Page F-25) [Table F-1 of the revised Toxicological Review] is inconsistent with the text on Starling et al 2017—text says high confidence and table say[s] low confidence.” This reviewer added “More broadly this information on correlation between PFASs is important for the discussion on confounding, so this summary information would be better addressed in the main document.”

EPA Response: The text was incorrect and was updated to match the low confidence rating noted in Table F-1. Beyond the appendix, EPA discusses some of the methodological challenges related to PFAS coexposures in Section 1.2. of the main document.

Comment: A reviewer stated that “the mere ‘slight’ totally [totality] of the evidence for developmental effects from the over 45 different epidemiological studies included in the draft assessment should not be considered sufficient for quantitative dose-response assessment (e.g., birth weight), but rather only for potentially supportive information for hazard identification" and that “EPA should reconsider their use of these epidemiological data for quantitative risk assessment/derivation of toxicity factors.”

EPA Response: Based on the hazard identification conclusion that the evidence indicates PFDA exposure is likely to cause developmental effects, and effects on fetal growth specifically, this outcome was advanced for dose-response modeling. Even though this judgment is based primarily on the available animal studies, with support from the human studies, once this judgment is made, the decision shifts to identifying the most appropriate and reliable study for deriving a quantitative estimate protective of all persons. The rationale for prioritizing the epidemiological over the animal studies is described in Section 5. This rationale includes using data from well-conducted human studies when such data exist. As noted in the evidence integration discussion in Section 3.2.8, 34 of the 45 studies across the 6 primary endpoints [fetal growth restriction (including both birth weight and length measures), gestational duration, postnatal growth, anogenital distance, birth defects, and spontaneous abortions] were either medium or high overall confidence, with the majority showing some evidence of associations for key endpoints anticipated to be measured with considerable accuracy. But, as noted, some methodological concerns (e.g., pregnancy hemodynamics in studies in which PFDA was measured during or after pregnancy) in the epidemiological database resulted in the slight judgment. As stated in the Toxicological Review, “the Wikström et al. (2020) study was prioritized for RfD derivation as it was a high confidence study that predominantly sampled maternal plasma during the first trimester thereby reducing uncertainty relating to pregnancy hemodynamics.” Therefore, EPA judged that the use of data from Wikström, 2020 for RfD derivation is reliable and sufficiently supported, with agreement from the majority of peer reviewers.

Comment: The same reviewer also stated that “Given the drastically different results across epidemiological studies and the mere 'slighť evidence of developmental effects across more than 45 such studies, EPA should reconsider use of a single epidemiological study (Wikström et al. 2020) for dose-response assessment of birth weight and RfD derivation and consider a meta-analysis and/or using the more definitive dose-response data from the mouse study for dose-response assessment of birth weight and RfD derivation.”

EPA Response: As noted above, even though the hazard judgment is based primarily on the available animal studies, with support from the human studies, once this judgment is made, the decision shifts to identifying the most appropriate and reliable study for deriving a quantitative estimate protective of all persons. Thus, given the similarities in findings across evidence streams and the availability of well-conducted human studies on the endpoint of interest, EPA considered higher quality epidemiological studies for use in dose-response analysis. As per EPA guidelines and the IRIS Handbook, EPA generally considers evidence from well-conducted studies in humans to be preferable to animal studies. As stated in the Toxicological Review, “the Wikström et al. (2020) study was prioritized for RfD derivation as it was a high confidence study that predominantly sampled maternal plasma during the first trimester thereby reducing uncertainty relating to pregnancy hemodynamics. EPA judged that a meta-analysis would not help further elucidate the weight of evidence or improve the quantitative estimate. For example, there was some concern that pooling studies across the most common unit of exposure expression (1 in-unit increase) would extrapolate beyond the range in most reported studies of PFDA. Overall, EPA concluded the use of data from Wikström, 2020 for RfD derivation is reliable and sufficiently supported, and this decision conclusion was upheld by the majority of peer reviewers.

Comment: The same reviewer also stated that “EPA should consider mouse data from the Harris and Birnbaum (1989) study for use as the primary basis for osRfD development based on developmental growth effects consistent with: (1) this mouse study providing the primary basis for EPA's developmental effects hazard conclusion; (2) the lack of factors that decrease certainty for fetal growth as evaluated in the mouse study (see Table 3-24 [Table 3-23 of the revised Toxicological Review]); and (3) the extensive epidemiological database merely being able to provide support for this mouse study with what amounts to ‘slight’ evidence for developmental effects across over 45 epidemiological studies.”

EPA Response: Please see the comment response above. In addition, as stated in the Toxicological Review, the PODs from the Harris and Birnbaum, 1989 mouse study are much less sensitive (6–7 orders of magnitude) than the PODs available for developmental effects from high confidence human studies. Therefore, an RfD based on the mouse data (Harris and Birnbaum, 1989) would not be considered as health protective compared with using the human studies.

Comment: The same reviewer also stated the use of “the mouse data (Harris and Birnbaum 1989) instead of epidemiological study data (Wikström et al. 2020) for dose-response assessment and osRfD derivation based on developmental growth effects would make EPA's assessment somewhat more consistent with ATSDR (2021), who found the epidemiology literature inadequate for use as the basis of deriving MRLs for PFAS.”

EPA Response: The Toxicological Review represents a comprehensive evaluation of the epidemiological literature and carefully considers the ability of the epidemiological studies to support dose-response decisions. The majority of the peer reviewers agreed with EPA's conclusions. Furthermore, as stated above, an RfD based on the mouse data (Harris and Birnbaum, 1989) would not be considered health protective.

Comment: The same reviewer also stated that “As the data from epidemiological studies provide only 'slighť evidence of developmental effects, including data from Wikström et al. (2020) that appears too uncertain and unsuitable for quantitative dose-response assessment, I suggest use of the mouse data (Harris and Birnbaum 1989) for dose-response assessment and osRfD derivation based on developmental growth effects.”

EPA Response: Please see responses above and below.

Comment: The same reviewer noted that based on the comments above, alternative studies and effects should be considered for the derivation of the lifetime RfD and suggested “One method to begin such an evaluation may entail sorting the study data extracted by NOAEL/LOAEL, BMD or a similar criterion that would allow EPA to readily identify the next most sensitive effects based on less problematic studies that are adequate for RfD derivation. However, any newly derived toxicity factor should be subject to external expert peer review (Tier 1 necessary revision).”

EPA Response: The Toxicological Review for PFDA estimated PODs for all the identified human health hazards with adequate data for dose-response analysis for the derivation of candidate toxicity values (liver, immune, male, and female reproductive, and developmental effects) (see Table 5-10). However, for the lifetime RfD, the derivation of candidate toxicity values for liver, male reproductive, and female reproductive effects was not attempted, given the high degree of uncertainty associated with using PODs from 28-day rat studies to protect against chronic exposure; these were the only suitable studies available for these outcomes. For immune effects, the only suitable studies for dose-response analysis were human studies. For developmental effects, PODs could be derived from high and medium confidence human studies; therefore, candidate toxicity values from the human studies were prioritized for selection of the lifetime RfD, given the general preference for well-conducted human studies over animal studies described in EPA guidelines and the notably more sensitive PODs. The majority of the external review panel (seven of nine reviewers) agreed with the scientific justification for the selection of the studies/effects used in the derivation of the lifetime RfD; one reviewer did not comment in response to this charge question.

#### Tier 2 Suggested Revisions

Comment: Two reviewers commented on the presentation of the studies and endpoints selected for dose-response analysis of the immune effects and provided suggestions to improve clarity. One reviewer noted “This section needs a clearer presentation of the extensive analysis that EPA did on dose-response and the link to the values that are later a major focus of appendices. In particular, the presentation would be improved by providing a more detail on clinical relevance and justification for the choices made and the uncertainties associated with the determinations.” The second reviewer added “Suggest providing prominent clarification in the immune section and this section which studies shown in the immune review were used to create the BDML analysis presented by Budtz-Jørgensen and Grandjean (2018). If available, it would be helpful if effect estimates and CIs for the combined cohort used for that study could be provided.”

EPA Response: Additional details on the BMD analysis and results were added to Section 5.2.1 to show the analytical details from the supplemental material shared by (Budtz-Jørgensen and Grandiean, 2018a) and used by EPA to derive the BMDLs. These include two new tables highlighting the effect estimates and confidence intervals of PFDA measured perinatally and antibodies measured at age 5 years, as well as PFDA measured at age 5 years and antibodies measured at age 7 years.

Comment: A reviewer made additional suggestions to improve the toxicity value derivation section, including “Suggest addition of a sensitive endpoint figure for the summary that helps highlight data rich, moderate and poor areas” and “Suggest adding clarification to the RfD table where the values came from and how they were derived (make things easier for your readers).”

EPA Response: Table 4-1 compares hazard conclusions for PFDA and other PFAS across EPA human health assessments, highlighting major data gaps for PFDA and PFAS in general. A footnote has been added to the organ/system-specific RfD tables (see Tables 5-12 and 5-16) in the Toxicological Review draft to clarify that the details of the BMD modeling approach and results can be found in Appendix C.

Comments: A reviewer agreed with the selection of the studies for immune effects but indicated “The authors need to opine on the use of these data for extrapolation of immune suppression for a population. Is the suppression delayed or slowed or permanently suppressed? Is this an adverse response that is recognized clinically with clinical studies to back up the adverse findings? What are the problems with using a remote population of people for use in the US? Is this the first time EPA has used this endpoint for IRIS?"

EPA Response: EPA defines an “adverse effect" as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism or reduces an organism's ability to respond to an additional environmental challenge” (U.S. EPA, 2002). Immunosuppression is considered a functional impairment. Whether or not the observed immunosuppression is eventually identified with clinical studies, it is clear that fewer antibodies reduce people's ability to respond to additional immunological challenges. EPA's interpretation of the immune effect was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c). Moreover, reduced antibody responses were used to support a 2016 NTP conclusion that PFOS and PFOA are presumed to be an immune hazard to humans NTP (2016).

Comments: In reference to the birth weight studies, a reviewer suggested that EPA “… acknowledge the broader range of PK differences associated with pregnancy that could also affect the interpretation of the human studies beyond the focused 'hemodynamic' currently discussed.”

EPA Response: EPA assumes the reviewer is specifically referring to the human birth weight studies. EPA is not aware of any evidence for specific PK differences associated with pregnancy, other than those already discussed, which are likely to impact the interpretation of those data. Note that due to the long half-life of PFDA, gestational dosimetry is determined by the PK and accumulation of PFDA in the woman over the years prior to pregnancy and thus the maternal body burden during pregnancy is strongly dependent on its PK in the nonpregnant woman.

### H.3.2 Public Comments on Noncancer Toxicity Value Data Selection and Modeling for the Lifetime ("Chronic") Reference Dose (RfD)

Comment: One commenter supported the use of human data as a basis for the derivation of toxicity values for PFAS citing a recent evaluation by the Health Effects Subcommittee of the New Jersey Drinking Water Quality Institute (DWQI, 2022). Another commenter disagreed with the derivation of the RfDs for immune and developmental effects, noting the following issues: “1) a failure to show clear mechanistic and quantitative links between the immunological endpoint and meaningful clinical outcome; 2) selection of critical studies based on nonrepresentative populations; 3) failure to consider the weight of evidence for reduction in birth weight in study populations; and 4) use of BMD modeling approaches that do not explicitly account for confounding by other PFAS.”

EPA Response: Regarding the reviewer's concern about uncertainty in the human database for immune and developmental effects, please see responses to relevant external peer-review comments above and below.

Comment: The same commenter expanded on the rationale for not supporting the selection of the immune effects as a basis for the RfD, noting that the evidence for associations between blood PFAS serum levels and reduced antibody responses is “weak" and reductions in antibody levels do not represent a meaningful clinical outcome and are not consistent with an increase in infectious disease. The commenter cited other reviews, health agencies, and expert panels that have reached similar conclusions (Antoniou et al., 2022; Garvey et al., 2023; ATSDR, 2021; COT, 2022; DoD 2022).

EPA Response: Vaccine immune titers are functional measures of adaptive immune response and important indicators of clinically relevant immunotoxicity; reduced antibody production is an indication of immunosuppression and may result in increased susceptibility to infectious diseases generally (i.e., not limited to those specifically studied). EPA defines an “adverse effect" as a “biochemical change, functional impairment, or pathologic lesion that affects the performance of the whole organism, or reduces an organism's ability to respond to an additional environmental challenge” (italics added) (U.S. EPA, 2002). Reduced antibody production is thus an appropriate effect for use as the basis for an RfD. The majority of the external review panel (seven of nine reviewers) agreed with the scientific justification for the selection of the immune effect used in the derivation of the lifetime RfD. Furthermore, EPA's interpretation of the immune effect was supported during the external peer review of the PFOS and PFOA Toxicological Reviews (U.S. EPA, 2022c). Moreover, reduced antibody responses were used to support a 2016 NTP conclusion that PFOS and PFOA are presumed to be an immune hazard to humans NTP (2016).

Comment: The same commenter listed several limitations in the Buddtz-Jørgensen and Grandjean (2018) study that they argue make it unsuitable as a basis the derivation of the RfD for immune effects, including: 1) baseline vaccine responses are highly variable (widely distributed in the population) but confidence intervals of the responses were not documented; 2) study did not account for transfer of maternal immunoglobulin G (IgG) to children, which may have interfered with the development of vaccine antibodies; 3) factors that can influence immune health such as nutrition and lifestyle were not discussed or controlled for; 4) co-exposures to other contaminants (other than PFOS and PFOA) were not sufficiently considered or independently evaluated by EPA; 5) study is based on an isolated population on the Faroe Islands that may not be representative of the U.S. population.

EPA Response: Regression coefficients and their standard errors for the results presented in (Budtz-Jørgensen and Grandjean, 2018a) were reported in (Budtz-Jørgensen and Grandjean, 2018b) and new tables have been added in Section 5 to make these details more easily accessible to the reader. Maternal IgG would not be expected to remain in children beyond infancy and therefore would not impact tetanus and diphtheria antibody concentration in 5- or 7-year-olds. The communities living on the Faroe Islands have similar lifestyles and nutrition that would not be expected to impact their children's antibody concentration outside of the body burdens of PFAS. Additional details of the potential confounding by PFNA, which was highly correlated with PFDA, revealed that PFNA was not a significant predictor of antibody concentrations and as such would not be expected to be a confounder.

Comment: The same commenter disagreed with the BMD modeling approach for immune effects stating that it is not scientifically supported and should be revised based on the following issues: 1) selection of a benchmark dose response of 5% as a threshold of significance for which there is no clinical relevance; 2) use of BMD/BMDLs that do not control for potential confounding by PFOS and PFOA; 3) lack of reporting on whether BMD modeling approach used by Budtz-Jørgensen and Grandjean (2018) had been independently validated by EPA, and failure to describe the multivariate approach in sufficient detail for evaluation by outside reviewers.

EPA Response: A BMR of 5% was considered, but ultimately not advanced in favor of using a BMR of ½-SD change in the distribution of antibody concentrations. In the absence of a clear definition of an adverse effect for a continuous endpoint like antibody concentrations, a default BMR of 1-SD change from the control mean may be selected, as suggested in EPA's draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). As noted above, a lower BMR can also be used if it can be justified on a biological and/or statistical basis. In the public external review draft, the selected BMR was ½ SD and an alternative BMR of 1 SD was shown for comparison. BMDLs were evaluated for potential confounding by PFOS and PFOA and when little potential confounding was indicated, some BMDLs that did not control for PFOS and PFOA were used as PODs. In other instances, BMDLs from models controlling for PFOS and PFOA were used as PODs. Extensive details of the regression modeling are presented in Appendix C.1. EPA did validate the BMDLs reported by Budtz-Jørgensen and Grandjean (2018) who used a BMR of 5% by checking that the regression coefficients reported in (Budtz-Jørgensen and Grandjean, 2018b) did yield the reported BMDLs; however, EPA used a different BMR of ½-SD change in the distribution of antibody concentrations as noted above.

Comment: A commenter stated that although the draft IRIS document discusses potential confounding by co-occurring PFAS, EPA did not adequately consider confounding by PFNA for the POD selected for the derivation of the RfD for immune effects. The reviewer noted in particular the strong correlations between PFDA and PFNA shown by Grandjean et al., (2012). Further, the reviewer requested clarification for considering associations with PFDA stronger than for PFNA (p. 3–58, line 6) stating “The statement about stronger associations for PFDA than PFNA may possibly be based on the fact that a doubling of serum levels represents a smaller numerical increase for PFDA than PFNA, because serum levels (at age 5 years) were lower for PFDA (geometric mean - 0.28 ng/mL) than for PFNA (geometric mean - 1.00 ng/mL) in this study.” Additionally, the reviewer suggested accounting for potential confounding by PFNA in the confidence descriptor for the POD quantification for the derived immune osRfDs (see Tables 5-11 and 5-15).

EPA Response: Additional text has been added to Section 3.2.2: Details of the regression modeling results (Budtz-Jørgensen and Grandjean, 2018b) show that PFNA was a nonsignificant predictor of both tetanus and diphtheria antibody concentrations with associations just 15% the strength of the PFDA association and thus PFNA could not have been a meaningful confounder. Table 5-15 has been updated to reflect the PFDA results were not considered to be confounded by PFOS, PFOA, and PFNA with callout to Section 3.2.2 and Appendix C.1.

Comment: A commenter stated that Table 5-7 (Table 5-9 of the revised Toxicological Review) should include the numerical value (2, 500 g) of the “public health definition of low birth weight.”

EPA Response: The public health definition of low birth weight was added to Table 5-9.

Comment: A commenter stated that the use of the ratio of human-to-animal clearance factors for interspecies toxicokinetic extrapolation “does not appear to be appropriate for development of Human Equivalent Doses (HEDs) from PODs from short duration studies of PFDA such as the 28-day rat studies since it is only applicable at steady-state. The duration of exposure in these studies (e.g., 28 days) is much shorter than the half-life of PFDA in the species used (e.g., male rats - 72 days; female rats - 54 days). Therefore, the serum PFDA levels are not at steady-state at the end of the dosing period in these short duration studies, since steady-state is not reached until after several half-lives of dosing (see Ito, 2011). For this reason, the serum PFDA level in rats at the POD will be lower than predicted by the equation on p. 3–22. Using this extrapolation approach when serum PFDA levels in rats have not reached steady-state would result in overprediction of the HED (i.e., result in a value higher than the actual HED). If serum PFDA data are available from short-term animal studies, it is suggested that measured serum PFDA levels (e.g., average serum levels over the course of the study, or maximum serum level at the end of the dosing period) be used to determine the POD (in benchmark dose (BMD) modeling, or as the NOAEL/LOAEL if appropriate). The human clearance factor can then be applied to the POD in terms of serum levels to determine the HED, was done for the human studies in Table 5-8 [Table 5-10 of the revised Toxicological Review]. This approach was used by the NJ DWQI to develop HEDs from laboratory animal serum data for PFOA and PFOS (DWQI, 2017; DWQI, 2018).”

EPA Response: EPA reevaluated the use of PK modeling and serum data from specific studies and has revised its approach for extrapolation of such results. Specifically, the end-of-study serum concentrations reported as part of the NTP 28-day study are now used directly via interpolation to estimate internal doses in that study and the similar (Frawley et al., 2018) 28-day rat study. PK data were not reported for the one mouse toxicity study evaluated (Harris and Birnbaum, 1989). so it was not possible to use direct interpolation similar to that used for the rat to extrapolate the mouse endpoint (decreased fetal body weight). It was concluded, however, that despite its uncertainty, EPA's PK model is more accurate than assuming steady state for mice. Hence, in response to this comment, EPA revised its analysis to avoid the assumption of steady state and used what was otherwise considered the most accurate approach possible for estimation of internal doses in rats and mice.

Comment: The same commenter also stated that “it should also be mentioned that internal (e.g., serum) PFDA levels did not reach steady-state in the 28-day studies because the half-life of PFDA in rats is much longer than 28 days" on p. 5–19, lines 11–13.

EPA Response: As noted just above, the revised approach for estimating internal doses for the 28-day rat studies (see Section 3.1.7 with supporting analyses in Appendix G.2) no longer assumes that PFDA levels in the animal reached steady state. Instead, the measured PFDA concentrations from the NTP 28-day rat study are interpolated directly to estimate the average serum concentration over the course of the study for use as the internal dose.

Comment: A commenter stated, “there was insufficient description and/or justifications for several assumptions made for PK extrapolation and for the UFs employed.”

EPA Response: EPA has clarified the rationale of assumptions made for PK extrapolation in Section 3.1.7 and Appendix G.2. The application of corresponding UF_A_ and UF_H_ are straightforward: UF_A_ is set to 3 when a PK model or chemical-specific PK data are used and UFH has a default value of 10 since the PK extrapolation does not account for interindividual variability. The description of the choice of UFA in Table 5-15 has been edited to reflect the revised extrapolation approach and the aforementioned rationale is outlined in the following two paragraphs. The use of UF_H_ = 10 for a noncancer endpoint is standard practice when human variability has not been experimentally addressed, and thus a brief justification is appropriate. The choice of UFs for duration extrapolation, including consideration of PK is discussed in considerable detail after Table 5-15 and the choice of UF_D_ (3) is explained in detail at the end of Section 5.2.1 and in Table 5-11.

Comment: A commenter stated that “In light of the inconsistent findings and additional uncertainty in estimating relevant exposures, it is not appropriate to rely on the epidemiological data to develop an RfD for reduced birth weight" and that EPA should reconsider using the mouse fetal body weight from the Harris and Birnbaum (1989) study to derive the developmental osRfD.

EPA Response: Please see responses to related external peer-review comments above and below.

Comment: A commenter stated that “The method of calculating human equivalent dose (HED) using human internal concentrations (i.e., HED = POD_int_ x Human Clearance) assumes that internal concentration (POD_int_) is at steady state. Given the estimated long half-life of PFDA in humans (i.e., 4 to 12 years), as well as the fact that there is a lack of data available to determine PK of PFDA in young children, it is unlikely that this method of calculating HED is appropriate for young children. While EPA discusses the uncertainty of extrapolating this dosimetry to children, it does not discuss the implications that these uncertainties may have toward the estimation of the RfDs for young children. This omission seems particularly important given that the RfDs derived from this review are based on putative effects of PFDA exposure in infants and young children.”

EPA Response: Existing data indicate that infants are born with body burdens that are within a factor of 2 of maternal levels and then receive significant exposure from lactation. Hence, the assumption is considered reasonable—children born to chronically exposed mothers may well be in a range of body burden close to steady state—and the assumption may underpredict risk from a potential large exposure through breast-milk ingestion. Further discussion on these points was added to the discussion of uncertainty in HED calculations in Section 3.1.7.

Comment: A commenter stated that “The explanation of the use of CDC (2018) data on birthweight of babies born in the U.S. and NHANES serum PFDA data for 2011–2012 to estimate the BMD and BMDL for 5% extra risk of low birth weight (Section C.1.2, starting on p. C-16) is unclear. It should be clarified so that a reader can readily understand the process and steps used in the evaluation.”

EPA Response: The Appendix C.1.2 discussion on birth weight modeling lays out how the birth weight data from the CDC natality file and the NHANES serum PFDA data were used in the estimation of study-specific BMDs and BMDLs. The CDC natality file is described as the source for the mean birth weight in the general U.S. population (along with the standard deviation) used in the modeling as well as the percentage of births that fall below the clinical definition of adversity. Equations C-3 and C-4 show how this percentage of low birth weight babies is used to calculate the BMR, and Equations C-5 through C-8 describe the calculation of the BMD and BMDL values for the Valvi et al. (2017) study (which is how all study-specific BMDs and BMDLs are calculated). Text on pages C-20 and C-21, along with Equations C-9 and C-10, clearly describe how the NHANES serum data is used to account for background exposures to PFDA in the estimation of the BMDs and BMDLs

Comment: The same commenter also stated that on page C-17, lines 14–16, “The link to CDC biomonitoring data for PFAS from 2011–12 does not work and more recent data are available. It is suggested CDC NHANES data from the same time period (2018) as the birthweight data cited earlier in the paragraph be used. CDC NHANES biomonitoring data for PFAS, including PFDA, for 2017–2018 are found at https://www.cdc.gov/exposurereport/data_tables.html.”

EPA Response: The link to CDC NHANES biomonitoring data was updated (https://www.cdc.gov/exposurereport/data_tables.html). The median of serum PFDA concentrations was 0.19 ng/mL for the period 2011–2012 and 0.20 ng/mL for the period 2017–2018 in NHANES. EPA performed BMD modeling using the median of serum PFDA concentrations for the period 2017–2018. The differences of BMDLs resulting from these two different assumptions ranged from 0 ng/mL to 0.01 ng/mL, depending on studies. Given the similarity of the results, no additional revisions were deemed necessary.

Comment: A commenter stated that “The proposed RfD for reduced birth weight relies on the findings of the study by Wikström et al. (2019) which reported significant effects in the highest exposure quartile in girls in relation to maternal serum concentrations in the first trimester in a longitudinal study in Sweden. The results contrast with those from other medium and high confidence studies which raises significant question about the selection of the endpoint for derivation of the RfD.” The same reviewer stated that the evidence base does not “support a link between PFDA and lower birth weight in humans and should not be relied on for the development of an RfD.”

EPA Response: As discussed above, this decision was supported by the majority of peer reviewers (seven of nine panelists; one panelist did not comment on this topic).

Comment: The same commenter also stated that “Appendix F of the draft IRIS supplemental document indicates that 11 of 22 studies (including several low confidence studies) show evidence of associations with PFDA and mean birth weight in the overall population, and that seven of those studies indicate comparable deficits for PFNA and PFDA. EPA states that considerable uncertainty is due to potential confounding by other co-occurring PFAS in the existing literature. Nonetheless, EPA did not attempt to control for confounding with other PFAS as part of its BMD modeling approach.”

EPA Response: As discussed above, given the uncertainty on the development of and interpretation of multi-PFAS models, EPA based their primary weight-of-evidence characterization on single-pollutant models since 45 studies helped inform this decision. This approach was supported by a majority of the peer-review panel. The very few studies that did examine multi-PFAS models are detailed in Appendix F.

Comment: A commenter stated that “the potential impact of other PFAS, especially PFNA, is an important limitation for use of these dose-response data from Wikström et al. (2020) as the basis for the PFDA RfD.” The same reviewer stated that this concern for confounding should be discussed in the “Confidence in quantification of the POD_HED_" (Tables 5-11 and 5-12) and recommended that “the potential for confounding by PFNA on the quantitative relationship between serum PFDA and decreased birthweight be further considered.”

EPA Response: Consistent with other endpoints, this source of uncertainty is addressed in detail in the first two sections of Table 5-11 ("Confidence in study used to derive osRfD" and “Confidence in Evidence Base supporting Hazard"), with the potential for confounding considered across multiple sections of the Toxicological Review and appendices (see responses to peer reviewers, above). Furthermore, the discussion for the “Confidence in quantification of the POD_HED_” focuses on the methods (e.g., BMD modeling, dosimetric adjustments) used in the calculation of a POD_HED_.

### H.3.3 External Peer-Review Comments on Noncancer Toxicity Value Data Selection and Modeling for the Less-than-Lifetime ("Subchronic") Reference Dose (RfD)

#### Peer-Review Comment Summary

In reference to charge question 3, five reviewers agreed with the selection of the studies and effects for the derivation of the subchronic RfD for PFDA. One reviewer provided a comment for future consideration (Tier 3) that the derivation of a subchronic RfD is not strictly necessary considering that the exposure will be chronic since the chemical is highly persistent. Citing the same concerns as in response to charge question 3, one reviewer disagreed with the appropriateness of these studies to derive subchronic RfDs for immune and developmental endpoints. Another reviewer refrained from commenting and the last reviewer did not explicitly state whether they agreed with EPA's conclusions. Most reviewers noted similarities in their responses to charge question 3 with their Tier 1 and Tier 2 comments made in responses to this question (see below).

A few new comments were provided. In reference to charge question 4c, one reviewer suggested adding any existing vitro studies to Table 5-16 for organ-specific endpoints and in reference to charge question 4d, another reviewer suggested that the uncertainty factor could be increased from 1, 000 to 3, 000 to estimate chronic osRfDs using these studies.

#### Tier 1 Necessary Revisions

Comment: A reviewer made the following comment in regard to the subchronic osRfDs derived for liver, male reproductive, and female reproductive effects “… it is imperative for EPA to acknowledge whether or not the dose-response data for a species selected for osRfD derivation (most often the most sensitive species) is known or likely to be (e.g., based on greater relevant biological similarities) the most predictive available for similar effects in humans or if dose-response data from another species might be equally relevant to humans and result in a significantly different (e.g., higher) osRfD.”

EPA Response: Responses to similar comments regarding human relevance of animal data for liver and male reproductive and female reproductive effects can be found above. In short, animal data for these effects are considered relevant to humans in the absence of evidence to suggest otherwise. Language has been added to the respective hazard sections to address this issue of human relevance. For example, the following text was added to the female reproductive section (see Section 3.2.5): “These findings are interpreted as relevant to humans in the absence of evidence to the contrary. This assumption is based on Guidelines for Reproductive Toxicity Risk Assessment (U.S. EPA, 1996).”

Comment: The same reviewer stated, “As with the lifetime RfD, I do not agree with the selection of these same studies and endpoints for subchronic RfD derivation (i.e., decreased serum antibody concentrations in Grandjean et al. 2012, decreased birth weight in Wikström et al. 2020).” Instead, the reviewer suggested the use of mouse data from the Harris and Birnbaum (1989) study as a basis for the subchronic RfD for developmental effects. Additionally, the reviewer noted that alternative approaches should be considered for the derivation of the subchronic RfD arraying the available NOAEL/LOAEL or BMDLs from less problematic studies to identify the next most sensitive effects (see comments on the lifetime RfD in Section A.3.1 for more details).

EPA Response: The Toxicological Review for PFDA estimated PODs for all the identified human health hazards with adequate data for dose-response analysis for the derivation of candidate subchronic toxicity values (liver, immune, male and female reproductive, and developmental effects) (see Table 5-10). Ultimately, the candidate values for immune and developmental effects were selected for the derivation of the subchronic RfD based on considerations for sensitivity and confidence decisions about the studies, evidence base, quantification of the POD, and overall osRfD. Of the nine external peer reviewers, five agreed with EPA's scientific justification for the selection of the studies/effects used in the derivation of the subchronic RfD and one disagreed (the other three reviewers abstained or did not provide an explicit opinion).

Comment: A reviewer stated that “it is important for EPA to transparently determine whether or not the effects on estrous cyclicity may be secondary to the observed decreases in body weight because if so, these effects should not be further considered for dose-response assessment (i.e., only the body weight effects) and this should be explicitly stated in the assessment.”

EPA Response: As noted above and pointed out by the respective reviewer, the Toxicological Review indicates that the PFDA-induced effects on estrous cyclicity are disproportionately more severe than changes in body weight. For example, the percentage of time spent in diestrus was statistically significantly increased by 27%-63% at ≥1.25 mg/kg-day compared with 12%-36% decreases in body weight at the same doses. Given that the PFDA-induced estrous effects are more severe than body weight changes, these data do not provide sufficient evidence to support that the estrous findings are likely to be secondary to body weight changes. Furthermore, without time course data showing effects on estrous cyclicity and body weight at multiple intervals, it is not possible to make definitive conclusions on the possible contribution of PFDA-induced body weight changes to estrous cyclicity effects.

#### Tier 2 Suggested Revisions

Comment: A reviewer commented “Table 5-16 lists organ specific endpoints for subchronic RfD consideration. The table and text provide good descriptions about the evidence base supporting the toxicity, along with confidence in the POD for a human and a summary confidence statement based on these factors. If there are in vitro studies supporting the toxicity endpoints (Confidence in evidence base supporting this hazard), it is worthwhile to include.”

EPA Response: The availability of in vitro studies or other mechanistic and supplemental information supportive of the identified human health effects is discussed in Section 3.2 NONCANCER HEALTH EFFECTS as part of the hazard judgments. This is also briefly mentioned in Table 5-15 under the discussion of the “Confidence in the evidence base supporting hazard” for each derived osRfD.

Comment: A reviewer agreed with the rationale for attempting the derivation of the subchronic osRfDs for liver and male and female reproductive effects but noted"… While the total composite uncertainty factor for these effects is already considerable (1, 000; Table ES-1), if lifetime osRfDs based on these effects (i.e., liver, male and female reproductive effects) are desired by EPA and/or considered useful for more complete risk assessments, EPA could consider increasing the total composite uncertainty factor to the upper end of their total uncertainty factor range (3, 000) to estimate chronic osRfDs (Tier 2 suggestion).”

EPA Response: As discussed in the Toxicological Review for PFDA, the available data for liver and male and female reproductive effects are limited to a 28-day study in rats (NTP, 2018). EPA judged there is too much uncertainty using PODs from a 28-day rodent study to protect against effects observed in a chronic setting and the magnitude of this uncertainty cannot be reasonably estimated without additional study (i.e., there is no information to support that increasing a UF an additional 3- or 10-fold would be expected to be health protective in a chronic setting).

### H.3.4 Public Comments on Noncancer Toxicity Value Data Selection and Modeling for the Less-than-Lifetime ("Subchronic") Reference Dose (RfD)

No public comments were provided.

### H.3.5 External Peer-Review Comments on Noncancer Toxicity Value Data for the Reference Concentration (RfC)

#### Peer-Review Comment Summary

In reference to charge question 3f, all nine reviewers agreed with EPA's decision not to derive an RfC for inhalation exposure to PFDA due to the lack of data, although one reviewer suggested that EPA explicitly state they have not identified a reliable PBPK/PK model for route-to-route extrapolation to support the decision not to derive an RfC (see below), and several reviewers provided Tier 3 future considerations (see peer-review report).

In reference to charge question 4e, seven reviewers agreed with EPA's decision not to calculate a subchronic RfC due to the lack of data, although one reviewer again suggested that EPA clearly state in the document, they have not identified a reliable PFDA PBPK/PK model from which they could perform route-to-route extrapolation (see below).

#### Tier 1 Necessary Revisions

Comment: A reviewer requested clarification on the availability of a PBPK/PK model for PFDA that could be used for route-route extrapolation, noting “If EPA has not identified a reliable PFDA PBPK/PK model that could be used for route-route extrapolation, then EPA's decision not to derive a subchronic or chronic RfC would be fully justified.”

EPA Response: Text was added to Section 5.2.4. in response to the reviewer's comment: “Existing PBPK models for PFDA were judged insufficiently reliable for estimating human dosimetry for any route of exposure, including possible route-to-route extrapolation. Additionally, no classical PK models were identified that included inhalation dosimetry to support the derivation of an RfC.”

#### Tier 2 Suggested Revisions

Comment: A reviewer agreed with the decision not to derive lifetime and subchronic RfCs due to the absence of data but indicated that “For PFASs with similar properties (e.g., long chain) read-across could be considered where PFAS-specific data is unlikely to be generated.”

EPA Response: The IRIS Toxicological Review of PFDA is only one component of the broader PFAS strategic roadmap at EPA (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021–2024). Other Agency efforts are aimed at evaluating hundreds of PFAS using new approach methods and a tiered toxicity testing strategy that can inform future category grouping and read-cross decisions to fill data gaps. Although the suggested analysis is outside the scope of the Toxicological Review, text was added to the Executive Summary in the main document to highlight these broader Agency efforts.

### H.3.6 Public Comments on Noncancer Toxicity Value Data for the Reference Concentration (RfC)

No public comments were provided.

## H.4 CHARGE QUESTIONS 5 AND 6 – NONCANCER TOXICITY VALUE PHARMACOKINETIC EXTRAPOLATION AND UNCERTAINTY FACTORS

5 Appendix A identifies the potential for pharmacokinetic (PK) differences across species and sexes as a key science issue and lays out a hierarchy for using relevant PK data in extrapolating doses between laboratory animals and humans. Section 3.1 evaluates and synthesizes the PK data in relevant species and sexes, and among human lifestages, up to the derivation of key PK parameters used in the subsequent analysis. However, the evaluation of existing PBPK models and a one-compartment PK model found that these options were not sufficiently reliable for use. Given the information available on potential interspecies differences in PFDA PK, EPA applied a data-derived extrapolation factor (DDEF) to POD values from toxicity studies in laboratory animals to estimate corresponding human equivalent doses (HEDs) in the derivation of the respective RfDs. Similarly, the estimated human clearance (CL) was used to convert internal dose POD (POD_int_) values from epidemiological analyses to corresponding HEDs.
  After publicly releasing the draft PFDA Toxicological Review, EPA evaluated recently published data for several other long-chain PFAS, described here (U.S. EPA, 2023, HERO ID 11181055), that are potentially relevant to evaluating PFDA dosimetry in women of childbearing age (see question 5c below).
  a) Is applying the estimated DDEF values for PFDA scientifically justified for conversion of PODs from animal toxicity studies to HEDs? If not, please provide an explanation and detail on a more appropriate approach.
  b) Is application of the human CL to estimate HEDs from PODint values scientifically justified? If not, please provide an explanation and detail on a more appropriate approach.
  c) Have the uncertainties in the DDEFs and human CL been adequately evaluated and described? In answering this question, please provide an explicit recommendation on whether or not EPA should expand its adjustment for menstrual fluid loss as outlined in (U.S. EPA, 2023, HERO ID 11181055) prior to finalizing the assessment. As these newer data are from other PFAS, note that such an expansion would be based on the assumption that the pharmacokinetic effect of pregnancy and lactation on PFDA is similar to that of the other PFAS (i.e., a read-across based interpretation).
6 Do the methods used to derive toxicity values for PFDA appropriately account for uncertainties in evaluating the pharmacokinetic differences between the experimental animal data and humans? EPA has evaluated and applied where appropriate uncertainty factors to account for intraspecies variability (UF_H_), interspecies differences (UF_A_), database limitations (UF_D_), duration (UF_s_), and LOAEL-to-NOAEL extrapolation (UF_L_) for PFDA.
  a) Is uncertainty in the derivation of the toxicity values scientifically justified and clearly described? Please describe and provide comments, if needed.
  b) For immune effects, a UFs of 1 and 3 were considered to account for extrapolation from less than lifetime human data; ultimately a UFs of 1 was selected. A UFs of 10 was not considered as the developmental period is recognized as a susceptible lifestage for these types of effects and therefore exposure during this time window can be considered more relevant than exposure in adulthood (U.S. EPA, 1991). Also important is the fact that, given PFDA's long half-life and the expectation that the children and their mothers have been exposed to elevated levels of PFDA for many years, the observed effects on immune response are considered to be the result of a cumulative, prolonged exposure. Uncertainties with regards to additional susceptible lifestages (e.g., old age) are addressed as part of the UFD. Does the provided scientific rationale support this decision? Please explain.
  c) For liver effects, a value of 3 is applied to extrapolate between effects in laboratory animals and in humans during the derivation of the subchronic RfD. Although PPARα dependence might support a value of UF_A_ = 1 if that were the sole pathway leading to these effects, evidence for the involvement of non-PPARα pathways is available in the PFDA database. Thus, uncertainty remains regarding the potential differences in sensitivity across species due to the involvement of both PPARα-dependent and PPARα-independent mechanisms. As such, the Toxicological Review concludes the available data are not adequate to determine if humans are likely to be equally or less sensitive than laboratory animals with respect to the observed liver effects and that a value of UF_A_ = 3 is warranted to account for the residual uncertainty in toxicodynamic differences across species. Please comment on whether the available animal and mechanistic studies support this conclusion and whether the analysis presented in the Toxicological Review is clearly documented.
  d) For liver, male reproductive, and female reproductive effects, a default value of 10 is applied for the UF_s_ when extrapolating from 28-day animal data to a subchronic exposure. Considering the potential for some health effects (prolonged diestrus, sperm measures, and increased liver weight) to worsen with increasing duration and the large uncertainty associated with the lack of chemical-specific data to evaluate the effects of subchronic exposure on liver, male reproductive, and female reproductive outcomes, the Toxicological Review concludes that application of a UFs of 10 is supported for the purposes of deriving the subchronic RfD from the 28-day toxicity data. Does the provided scientific rationale support this decision? Please explain.
  e) Are the provided rationales for the remaining uncertainty factors (UF_L_, UF_D_, UF_H_) scientifically justified and clearly described (to inform the UF_H_, the assessment evaluates and considers the available evidence on potential susceptibility to PFDA within different populations or lifestages, including any potential impacts from early life exposure to PFDA on children's health or health later in life, although few studies on susceptibility were available)? If not, please explain.

### H.4.1 External Peer-Review Comments on Noncancer Toxicity Value Pharmacokinetic Extrapolation

#### Peer-Review Comment Summary

- In reference to charge question 5a, six reviewers commented that the approach is scientifically justified, with two of these reviewers commenting that the presentation in the document is complicated and the justification is not readily apparent (see below) in the document text. One reviewer disagreed with the DDEF approach and encouraged EPA to pursue a PBPK model beyond what has been published by EPA authors (such as Bernstein et al., 2021) and to consider harmonization or read-across from other PFAS (see below). Two reviewers declined to comment.
- Specifically in reference to charge question 5b, two reviewers explicitly agreed with the application of human clearance values to calculate HEDs from POD_int_ values, and another reviewer agreed with the approach if a reliable value can be calculated for human clearance.
- In reference to charge question 5c, two reviewers stated the uncertainties are adequately evaluated and described, whereas three reviewers commented that further discussion of the uncertainty is needed (see below). One reviewer recommended EPA not adjust for menstrual fluid loss given the adjustment would rely on many assumptions about menstrual flow and another reviewer agreed with the notion that the adjustment requires many assumptions. Conversely, three reviewers stated EPA should expand the adjustment to account for menstrual fluid loss (see below; for Tier 3 future considerations provided on this topic, please see the peer-review report).

#### Tier 1 Necessary Revisions

Comment: A reviewer stated “The presentation of the complex relevant data landscape on PFDA and shortcomings of the single available PK model can be improved substantially. Given the shortcomings of the underlying data from both animals and humans the DDEF approach is justified in this case, with the caveat that there needs to be an Evidence Integration section in the Appendix AND main PFDA document that lay[s] out the logic of the choices made more clearly. Most importantly, this section needs to explicitly lay out the uncertainties as judged by the scientists who have done this extensive evaluation of the existing data.”

EPA Response: EPA has revised the text throughout Section 3.1 to improve clarity. Besides presentation of the range of values for each PK parameter in each corresponding section (e.g., Section 3.1.2) an analysis of the parameters and approach used for extrapolation is provided in Section 3.1.7. Evidence synthesis summaries have been added at the end of the sections on absorption (see Section 3.1.1), distribution (see Section 3.1.2), excretion (see Section 3.1.4) and the approach for pharmacokinetic extrapolation (see Section 3.1.7). Since there is no evidence for metabolism and that section is a single paragraph, a corresponding synthesis was not needed there. The synthesis for PK extrapolation also addressed the evaluation of PBPK and PK modeling (Section 3.1.6). Each of these new subsections addressed the corresponding results from Appendix G; thus, additional evidence integration pieces for that appendix would be duplicative.

Comment: A reviewer stated that “It was not clear from the description that assumptions are based on animal data, which introduces substantial uncertainty.”

EPA Response: While the clearance of PFAS clearly differs in a substantial way between humans and animals, EPA interprets this to result from a quantitative difference rather than some fundamental difference in mechanism. Because of the much more limited PK data in humans than in experimental animals, extrapolation of features of animal PK data to humans is necessary. However, considering the long-standing knowledge from pharmacological science that most of the processes involved are similar in animals and humans, and consistent with EPA guidelines and practice in this area, EPA does not consider these assumptions (i.e., that absorption and distribution are similar) to introduce substantial or unreasonable uncertainty. Such assumptions are necessary for animal-to-human extrapolation in the absence of additional evidence.

Comment: A reviewer stated that “it is important to consider that not all women menstruate, bear children or breast feed. Those who do not would of course have lower clearance than those who do.”

EPA Response: As noted elsewhere in these responses, based on reexamination of empirical data EPA is no longer assuming that menstrual fluid loss is a significant, general mechanism of clearance. Extrapolation of nondevelopmental health effects is conducted without application of this factor, i.e., for women whose clearance is no different from men and postmenopausal women. Hence, the evaluation of health effects in adult women does not presume they have children (and breastfeed).

Comment: A reviewer stated “The reasons stated why data-derived extrapolation factors (DDEFs) were used are because of the publication of a poor quality PBPK model for PFDA (Kim et al. 2019) and the inability to predicted plasma levels in rats gavage dosed with PFDA daily for 28 days (NTP 2018) using a compartment model calibrated using single dose PFDA PK data (IV and oral). I think the EPA should continue to resolve these issues and use a PBPK model beyond what has been published by EPA authors (Bernstein et al. 2021).”

EPA Response: EPA has evaluated PK data from various PFAS and reached the conclusion there are fundamental aspects of PFAS PK that are not yet understood, which are considered necessary for a proper PBPK model to be sufficiently sound for application. Considering also that the rodent data are not key drivers of this assessment, the use of more traditional PK analysis and direct evaluation of rat PK data from the NTP 28-day bioassay was deemed sufficient and retained. Further, note that the majority of panelists did not support revision of the PBPK model but indicated that a simpler PK-informed approach would be sufficient.

Comment: The same reviewer also stated “More work is needed to better understand the pharmacokinetics of PFDA for repeated animal exposures in the context of a PBPK model.” The reviewer further stated “The cost of not continuing to modify the Kim et al. published PBPK model for PFDA is problematic. To derive subchronic osRfDs a PBPK model would be superior to any other methodology because a PBPK model includes organs and tissue groups in a physiologically relevant manner and can predict internal organ dosimetry.”

EPA Response: Please see above response, noting that new experimental data will likely be needed to understand the complex observations of tissue versus serum data currently available for PFDA and other PFAS.

Comment: A reviewer made a recommendation to “Edit and expand the discussion on the estimation of human clearance to state explicitly and clarify that this estimation incorporates uncertainties associated with assumptions that are based on animal data regarding the ratio of fecal/urinary clearance of PFDA.” The reviewer made a recommendation to “Briefly summarize and explain the approach followed for replicating and adjusting the PBPK model of Kim et al. (2019), i.e., using the R templates provided in Bernstein et al. (2021); incorporate this information in Appendix G following the analysis of the -1 and 2-compartment PK models. (Please see Answer to Charge Question 6a for more details).”

EPA Response: EPA has revised the discussion of the human PK data to better address its uncertainty. Note that EPA has shifted its analysis to reduce reliance on quantitative animal PK data for the estimation of human clearance. However, as noted in the document, the estimate of human fecal clearance is based on biliary excretion data from only five subjects who were being treated for various diseases (Fujii et al., 2015). which EPA considers as providing an uncertain estimate of clearance in the population as a whole. Further, EPA notes Fujii et al. (2015) obtained its estimate of fecal clearance, “Assuming a volume distribution of 200 mL/kg (based on previous reported mouse experiments.” This assumption was needed to estimate the extent of enterohepatic recirculation for PFOA (for which a half-life was established in humans independently), which was then assumed to also apply to PFDA. Given the overall landscape of human data for PFDA, with no time-course or controlled exposure data that could be otherwise used to independently estimate the half-life or volume of distribution, EPA considers all avenues of estimating human clearance to involve significant uncertainty. These estimates still clearly indicate a range of clearance in humans much lower than would be predicted by a BW^3/4^ scaling from rats or mice, and hence are preferred, but their uncertainty is important. Thus, this uncertainty is acknowledged and discussed in multiple places in the revised Toxicological Review.

In addition, further details have been added on the attempt to replicate the results of Kim et al. (2019), also pointing the reader to the Bernstein et al. (2021) paper wherein more details are provided (see Section 3.1.6).

Comment: The same reviewer made a recommendation to “Explain (in Appendix G) why other published models (e.g., Fàbrega et al., 2015), were evaluated as not adequate for supporting pharmacokinetic calculations.” The reviewer also made a recommendation to “Check and ensure that values of pharmacokinetic properties listed in the document match those reported in their cited sources: an example is such as, e.g., the value of 215–300 days for beta- or single-phase half-life of PFDA in male rats attributed to Dzierlenga et al. (2019).”

EPA Response: An evaluation of the Fàbrega et al. (2015) model was added to Section 3.1.6 (which also includes the review of Kim et al. (2019)), noting that it too relies on a critically flawed assumption regarding tissue distribution and contains several other issues preventing its use (see Section 3.1.6).

In addition, the half-life values attributed to Dzierlenga et al. (2019) have been corrected. Other cited values were checked.

Comment: A reviewer stated that “EPA should expand its adjustment for menstrual fluid loss (as outlined in (U.S. EPA, 2023a)) prior to finalizing the assessment if EPA judges the alternative/modified adjustment to be associated with less uncertainty than that associated with not conducting such an adjustment.”

EPA Response: Per previous responses, the explicit assumption on menstrual fluid loss was removed for this Toxicological Review based on NHANES data for PFDA.

#### Tier 2 Suggested Revisions

Comment: A reviewer stated that more discussion of the magnitude and directionality of uncertainty is needed regarding the pharmacokinetic extrapolation applied in the draft assessment. The reviewer further recommended “adding a table of uncertainties and prioritization for evidence integration.”

EPA Response: A description of directionality was added when the uncertainty is clearly unbalanced in one direction. While EPA has not added a table of key uncertainties, the new evidence synthesis subsections noted above identify key uncertainties in the corresponding components of ADME and PK.

Comment: A reviewer stated the HED calculation could be strengthened by utilizing individual data on serum concentrations and immune response. The reviewer also recommended “a probabilistic type of assessment of HEDs using human serum concentrations of PFDA.”

EPA Response: The HED calculation from serum concentrations is a linear conversion, multiplication by CL. Hence, performing this conversion before versus after summarizing the data would not alter the result. An established EPA process for integrating probabilistic PK and dose-response analyses does not currently exist. Further, note that the simpler PK approach was supported by the majority of panelists.

Comment: The same reviewer stated that “The big problem is that protein transporters (liver and kidney) and serum and tissue (?) protein binding are responsible for the slow whole body CL rate. A PBPK model is greatly favored over the current approach because the key biological factors can be explicitly described and used in predictions. Animals are much different than humans. The use of allometric relationships is of little or no value for across species scaling.”

EPA Response: As noted above, EPA agrees that a full PBPK model that includes all these features would be preferred; however, no such adequate model exists.

Comment: The same reviewer stated that because PK data are available for PFDA, those data should be used rather than read-across. “Read-across is helpful to provide evidence of going down the right path in terms of PK.”

EPA Response: EPA agrees that, to the extent possible, PFDA-specific data should be used. However, as noted above, the estimate of human fecal clearance by Fujii et al. relies on a read-across of GI resorption from PFOA (and the V_d_ for PFOA estimated for mice). The revised Toxicological Review now uses the fecal clearance of Fujii et al. since it is based primarily on human PK data. But while some PK data are available for PFDA in humans, there are also significant data gaps that can only be addressed by read-across, extrapolation from animals, or a combination of the two such as was done by Fujii et al. The human PK data for PFDA (i.e., that can be used to estimate PK parameters) are more limited than for other PFAS. Thus, this uncertainty is emphasized in several places throughout the revised Toxicological Review.

Comment: A reviewer made a recommendation to “Evaluate and, if feasible, apply options for alternative animal to human extrapolation approaches that do not require steady-state assumptions inconsistent with short-term study data.”

EPA Response: As described above and in the revised document, EPA's revised analysis was revised to avoid the assumption of steady state for evaluation of dosimetry in the short-term rat and mouse bioassays.

Comment: A reviewer stated that “Modeling should be sure to consider enterohepatic recirculation and kidney resorption.”

EPA Response: These processes are implicitly included in classical PK analysis of various data, specifically that use empirical data to identify overall clearance. In particular this is why the empirical clearance is slower than would be predicted by glomerular filtration of unbound PFDA for male rats and humans, as discussed in Section 3.1.5. As discussed above and detailed in the discussion on excretion in humans (see Section 3.1.4), the estimate of human fecal clearance is based on an estimated enterohepatic recirculation of 98%. While EPA recognizes that renal resorption is a likely factor, the available data do not allow for an estimation of dose-dependent urinary clearance in humans and EPA judged that a specific description of renal resorption as a saturable process does not improve the internal dose estimates versus the empirical estimation of total clearance obtained (see also Appendix G.1.4).

Comment: A reviewer made a recommendation to acknowledge the finding of differences in a variety of pharmacodynamic parameters including protein binding during pregnancy with linked comment on potential for breast milk lactational pharmacokinetic considerations. Addition of references and several sentences would be suggested.”

EPA Response: The following text has been added to Section 3.1.2, “Specific mechanisms known to impact the distribution of substances during pregnancy are the changes in blood volume (hemodynamics) and concentration of serum proteins. A review by Feghali et al. (2015) states that serum concentration of albumin decreases 13% by gestation week (GW) 32, but that the overall serum volume increases by 42% by GW 38. The net impact of both these changes is then a 0.87 x 1.42 = 1.24-fold increase in the total amount of albumin in the serum, which would suggest 24% lower distribution to various tissues (since there is greater total binding in the serum), including the fetus, compared with what one would otherwise predict. However, the evaluation of fetal distribution just described is based on empirical fetal concentration data, which already depend on and therefore implicitly account for variation in maternal serum binding. Further, since we lack precise measurements of the V_d_ in human adults (specifically, the pregnant mother) versus the fetus and amniotic fluid, and there are no data on excretion (clearance) during pregnancy, the specific contribution of these changes in maternal blood volume and albumin concentrations to the overall empirically observed PFDA concentration changes cannot be quantified.”

The discussion of lactational distribution has been given its own subheading to better emphasize that component and the following text has been added, just after the current text stating that the milk/maternal serum ratio is 0.03:1: “It should be noted that this empirically measured ratio implicitly accounts for the level of serum binding in the breastfeeding mother, that is, the extent to which that may differ from women outside of the gestational and lactational lifestages. While this low ratio indicates a rather limited level of lactational transfer to infants, the total intake by a breastfed infant will also depend on the milk ingestion rate. For an exclusively breastfed infant, the total exposure by this route could be quite large. Considering that breast milk is a key source of nutrition for infants and the lack of studies demonstrating a specific hazard from this route of exposure, versus in utero exposure and other possible routes for infants, the best option for limiting developmental exposure to PFDA is to limit maternal exposure, which will reduce both in utero and lactational exposure of the offspring.”

Additional text on the significance of lactational transfer was also added to the discussion on uncertainty in HED calculations for PFDA in Section 3.1.7, per the response below.

A brief discussion of this minimal uncertainty is now included.

### H.4.2 Public Comments on Noncancer Toxicity Value Pharmacokinetic Extrapolation

Comment: A commenter recommended that “the discussion of exposure to PFDA through breast milk be expanded and that the importance of exposure to PFDA in breastfed infants be given more emphasis. The draft IRIS document (p. 3–11, lines 7–10) states that the breast milk:maternal serum ratio of 0.03:1 indicates 'a rather limited level of lactational transfer to infants.' This statement may be incorrectly interpreted to mean that breast milk is not an important exposure route to infants for PFDA. However, even though only a few percent of the PFDA in maternal serum is transferred to breast milk, it is well established that infants receive substantial doses of long-chain PFAS such as PFDA through breast milk because of the bioaccumulation of these PFAS in maternal serum and the large volume of breast milk ingested by infants relative to their body weight. For example, see Goeden et al. (2019) and Post (2022). While PFDA was not specifically evaluated by Fromme et al. (2010), the data presented in this study demonstrate that serum levels of other long-chain PFAS with breast milk:maternal serum ratios similar to that of PFDA are several fold higher in breastfed infants than in their mothers. The elevated exposure to PFDA and other long-chain PFAS in breastfed infants is important because infants are a sensitive subpopulation for the developmental and other (e.g., immune) effects of these compounds. Notably, the higher exposure of breastfed infants to long-chain perfluoroalkyl acids, including PFOA, PFOS, perfluorohexanoic acid (PFHxS, and PFNA, has been considered in the drinking water guidelines developed by several states (see Post et al., 2021) and in the draft RfDs for PFOA and PFOS presented in the recent draft EPA (2023a, b) health effects assessments of these PFAS.”

EPA Response: As noted above, the potential significance of lactational transfer is now stated in the (new) subsection on human lactational distribution. Further discussion of the significance of lactational transfer was also added to the discussion on uncertainty in HED calculations for PFDA in Section 3.1.7, per the response below. However, EPA considers specific predictions of lactational transfer to be highly uncertain given the very limited data on PFAS PK in infants. Also, EPA specifically evaluated the model of (Goeden et al., 2019) and identified a mass balance error in the Excel spreadsheet used. A large bolus to the infant is still predicted when this error is corrected but not as large as shown in that publication. Given the overall uncertainty in a potential estimate of lactational transfer due to the data limitations noted in the document, EPA does not believe that further elaboration on this topic would meaningfully add to the evaluation of risk.

Comment: A commenter suggested “adding more introductory information (p. 3–7, lines 28–30) to convey the importance of exposure to PFDA during developmental lifestages and to introduce the detailed discussion that follows.”

EPA Response: A detailed presentation of exposure information falls outside the scope of an IRIS Toxicological Review. The brief summaries included in the Toxicological Review are for context and are neither comprehensive nor a primary resource on these topics. Thus, additional information was not added.

Comment: "p. 3–12, lines 4–6. It is unclear why a comparison of PFDA to PFHxS is made here regarding chemical stability of PFDA. All PFAAs, short- and long-chain, are chemically stable and are not metabolized, and there is no reason to use PFHxS as a “benchmark” for chemical stability. Also, “C6" refers to PFHxA, not PFHxS.”

EPA Response: The comparison is to “other shorter length PFAA chemicals” with PFHxS only mentioned parenthetically as an example: “The findings are expected since PFDA is a long-chain (C10) PFAA with chemical stability similar to that of other shorter length PFAA chemicals (e.g., perfluorohexane sulfonic acid, PFHxS).” It is not presented as a “benchmark" for chemical stability, nor is the term “benchmark" used. It is a valid example of shorter-chain PFAAs and is a C6 PFAS, so no edits were made.

Comment: "p. 3–12, lines 6–8. The sentence about potential metabolism after inhalation or dermal exposure appears to be unnecessary and potentially misleading. PFDA does not undergo chemical reactions in the body, and there is no reason to believe that there might be metabolism after inhalation or dermal exposure.”

EPA Response: Since some chemicals have different biological fates depending on the route of exposure, EPA believes the sentence is appropriate to make the point that such is not expected for PFDA.

Comment: "p. 3–12, line 15. It is important to discuss that the ‘sex-specific elimination' in rats mentioned here for other PFAS is very different than for PFDA. The excretion rate of several other PFAS (e.g., PFBA, PFHpA, PFOA, PFNA, PFHxS) is faster in females than in males, and this difference is dramatic for some PFAS. For example, the rat half-life of PFOA is 4–6 days in males and 2–4 hours in females, and for PFNA, it is 30 days in males and 1–2 days in females. See Table 17-7 of the ITRC PFAS Technical and Regulatory document at https://pfasl.itrcweb.org/17-additional-information/#17_2 (https://pfas1.itrcweb.org/17-additional-information/#17_2). In contrast to these other PFAS, the rate of excretion of PFDA in rats is somewhat faster in males than in females, as indicated by the PFDA half-life in male rats that is 33% lower than in female rats (Table 3-3).”

EPA Response: EPA agrees that the sex difference observed for other PFAS does not translate to PFDA in rats. EPA's analysis indicates no significant difference between male and female rats, and the text was revised to indicate that this is in contrast to other PFAS.

Comment: "p. 3–12, lines 23–24. It is not clear if this statement about fecal excretion applies only to rats or also applies to humans and other species.”

EPA Response: A paragraph on the limited human data for fecal excretion has been added.

Comment: "p. 3–12, line 24 - p, 3–13, line 2. The first two studies discussed here (Kudo et al., 2001; Vanden Heuvel et al., 1991) used high doses of PFDA (20 and 25 mg/kg) and reported much more excretion in the feces as compared with the urine. In third study (Kim et al., 2019), a much lower dose (1 mg/kg; Table 3-2) was used, and a higher percentage of excretion was in the urine. Could this difference from the other two studies have been due to the much lower dose?"

EPA Response: For most PFAAs that EPA has analyzed, excretion appears to be more rapid at higher doses and this is attributed to saturable resorption in the kidneys, leading to an expectation that urinary excretion will increase with dose, not decrease. In general, however, it is possible that the shift for PFDA is dose dependent, and a sentence indicating this hypothesis was added.

Comment: A commenter suggested “that additional information be added about infants' exposure to PFDA through breast milk" on p. 3–16, lines 22–35.

EPA Response: As IRIS Toxicological Reviews do not include detailed exposure information, the statement that PFDA transfer into breast milk is an exposure route for the breastfed child is considered sufficient.

Comment: A commenter stated “that the two compartment PK model developed by Kim et al. (2019) was abandoned prematurely" and that “The effort to update the Kim et al. model, however, could greatly reduce uncertainty in extrapolating from animals to humans.”

EPA Response: Please see above responses relating to the multicompartment PBPK model of Kim et al. (2019) and EPA's evaluation and decision not to incorporate this model in the assessment.

Comment: "p. 3–24, paragraph beginning on line 29. This paragraph discusses uncertainties in the extrapolation to developmental exposure and dosimetry in children, but it does not mention exposure through breast milk. As above, breast milk is an important exposure source in infants, and this should be discussed here.”

EPA Response: The discussion on uncertainty in HED calculations for PFDA in Section 3.1.7) was revised to include a discussion of PFDA exposure to children in breast milk:

"Studies evaluating the impact of breastfeeding on other PFAS have shown that it can be a significant route of exposure for the infant. For example, Koponen et al. (2018) showed a significant increase in the serum concentration of PFOS, PFOA, PFNA and PFHxS in children at 1 year of age with months of breastfeeding. A linear regression of the data estimated an approximately 3-threefold increase in PFNA and 8-eightfold increase in PFHxS concentration from 12 months of breastfeeding versus children who were not breastfed. A significant decline was then observed in serum concentrations in children at 6 and 10.5 years of age compared with 1 year (Koponen et al., 2018). Although the median ratio of PFDA concentration in breast milk to maternal serum was only 0.03 (3%) (Liu et al., 2011), breastfeeding was found to reduce PFDA serum concentrations of women who had breastfed by an average of 1.3% per month of breastfeeding (Kim et al., 2020). For comparison, the estimated average human half-life of 4.7 years corresponds to a decline of about 1.2% per month. This rate of lactational transfer is from an adult woman who has accumulated PFDA over her lifetime to a child that is 5%-10% of her body mass and thus appears to represent a significant source of exposure to the child. However, the exact extent of this transfer and the resulting time-course of PFDA in the child is unknown. The range of PFDA concentrations in breast milk found by Liu et al. (2011) was <0.001–0.070 ng/mL, over 70-fold, while the range in maternal serum was 0.052–1.271 ng/mL, about 24-fold. Two other sources of variability in the lactational transfer of PFDA to children is the source and exclusivity of breastfeeding in the child's nutrition. Not only do these results indicate wide variability in the amount of PFDA in breast milk, but in the transfer rate and efficiency from the mother by that route.”

Comment: A commenter stated that “a key assumption of the DDEF approach is that male and female rats/mice are sufficiently comparable to male and female humans in their responses to PFDA. This foundation follows from guidance (USEPA 2014) that specifies that there should be a demonstrated concordance of the metabolic processes involved for the chemical between human and animal models. While the draft assessment describes the four aspects of PK (i.e., absorption, distribution, metabolism, excretion) in both animals and humans, there is no explicit discussion of similarities and differences in responses between humans and non-human animal models. Because the underlying logic of the DDEF approach relies on concordance between human and animal models, particularly in the absence of a data-based PK-model, EPA should explicitly demonstrate that that sex-based PK patterns found in rats and mice are a reasonable choice when computing DDEF for humans.”

EPA Response: In the case of PFDA, there is strong concordance between the “metabolic processes involved” in rats and humans since neither species metabolizes PFDA. There is an expected concordance between the expected response (pharmacodynamics) in rats and humans, but this concordance need not be sex specific. For example, hepatic effects observed in male rats may be predictive of hepatic effects in women, and the approach used assumes this is the case. Discussion of the general expected concordance of toxic effects between rats and humans is a component of the hazard identification, not the dosimetric extrapolation. The specific method of extrapolation does not depend on the concordance, given that the rationale is provided.

The use of sex-specific PK data or parameters for rats and mice simply accounts for the estimated PK in male versus female animals used for toxicity testing, to estimate the corresponding internal doses. Generally, when predicting the internal dose for an endpoint observed in female rats, sex-specific PK data for female rats should be used, and vice-versa for male rats. However, for PFDA, there is not a significant difference between the sexes. Thus, sex-specific parameters are not used for estimating dosimetry in humans.

### H.4.3 External Peer-Review Comments on Noncancer Toxicity Value Uncertainty Factors

#### Peer-Review Comment Summary

- In reference to charge question 6a, four reviewers agreed that the uncertainty in the derivation of toxicity is scientifically justified and clearly described, while one reviewer commented that there were inconsistencies in the chosen uncertainty factors (see below) and that EPA should reparametrize the Kim et al. (2019) PBPK model (provided in response to question 6ai). Other reviewers declined to comment or did not specifically state their response to the question (see comments below; reviewers also provided a future consideration on this topic; see peer-review report).
- In reference to charge question 6b, five reviewers stated that the selection of an uncertainty factor of 1 to account for extrapolation from less than lifetime human data for immune effects is scientifically justified, while one reviewer thought the justification was unclear (see below) and other reviewers did not answer this question.
- In reference to charge question 6c, seven reviewers agreed with an uncertainty factor of 3 to extrapolate between effects in laboratory animals and in humans during the derivation of the subchronic RfD for liver effects, while one reviewer recommended a factor of 10 (see below).
- In reference to charge question 6d, six reviewers agreed that the justification is sufficient for selecting a UF_s_ of 10 when deriving a subchronic RfD for liver, male reproductive, and female reproductive effects, while one reviewer suggested use of an animal/human PBPK model and another reviewer recommended considering data from structurally related PFAS could help inform the UF_s_, which was also suggested by one of the reviewers that agreed with the justification (see below). One reviewer did not comment.
- In reference to charge question 6e, seven reviewers agreed that the remaining uncertainty factors are scientifically justified and clearly described, while an eighth reviewer suggested EPA could use language accessible to audiences without a background in epidemiology in explaining tools used to differentiate the health effects of PFDA when the chemical is part of a mixture of exposures (see below).

#### Tier 1 Necessary Revisions

Comment: A reviewer stated that they were “not supportive of the use of the value of 3 to account for lack of a chronic study in animals.”

EPA Response: EPA assumes the reviewer is referring to the UF_D_; the respective charge question was specifically focused on the UFA. The lack of a chronic study in animals was not the reason this value was selected, although this was highlighted as a data gap. Rather, a UF_D_ of 3 and a UF_D_ of 10 were both considered due to the limited database (e.g., the lack of a two-generation reproductive toxicity study). Based on the available data for PFDA and structurally related PFAS (e.g., PFOA), the lack of a multigenerational reproductive study is not considered a major concern as developmental reproductive effects do not appear to represent a more sensitive target in the current studies. Furthermore, the database for PFDA does contain well-conducted studies on a range of health outcomes in multiple species, including sensitive evaluations of developmental and immune endpoints in humans. Remaining gaps in the database for PFDA include the lack of an evaluation of postnatal effects in animals, specific investigations of potential thyroid or neurodevelopmental effects (which have been shown to be potentially sensitive outcomes for other PFAS), and long-term studies in multiple species. Based on these residual uncertainties, a UF_D_ of 3 was chosen.

Comment: Two reviewers suggested that EPA consider whether data from structurally related PFAS could help inform the UF_S_ value for one or more of these effects with one of these reviewers further suggesting that “if they have already done so, explicitly state this in Section 5.2.3 of the draft assessment.”

EPA Response: In the Toxicological Review for PFDA, toxicity data from structurally related PFAS were incorporated to partially address data gaps for PFDA as needed. For example, conclusions from structurally related PFAS were used as rationale to select a UF_D_ of 3. For the selection of the UFs in the derivation of the subchronic osRfDs for liver and male and female reproductive effects, the chemical-specific data for PFDA indicate a potential to worsen with increasing duration. For example, PFDA induced a continuous state of diestrus in 100% of rats treated at the highest dose tested indicating that it is possible that PFDA-induced effects on estrous cyclicity could become more sensitive or lead to more severe downstream effects like infertility with longer exposure durations. Given that such conclusions are based on PFDA-specific data, it was not considered appropriate to prioritize toxicity data from structurally related PFAS to inform the selection of the UF_s_.

Comment: A reviewer stated that “The lack of consideration of women who are not menstruating due to amenorrhea, exercise or being on contraception should be noted in the analysis.”

EPA Response: On the basis of further analysis of NHANES data, showing differences between men and women in serum levels of some PFAS but not PF[underlined: D]A, EPA has now concluded that menstrual fluid loss is unlikely to be a general process for PFAS clearance, although women appear to preferentially clear some PFAS more rapidly than men. The NHANES data are presumed to indicate the average case for all women, including those who do not menstruate for various reasons. Thus, this consideration no longer applies.

#### Tier 2 Suggested Revisions

Comment: A reviewer suggested “defining the abbreviations in Table 5-9 [Table 5-11 of the revised Toxicological Review] (this is buried and hard to find), explain why the math doesnť add up (adding uncertainty factors as shown does not produce the sum shown), and make it clear that the one to the right is the sum.”

EPA Response: The definitions for the individual uncertainty factors can be found in the list of “Abbreviations and Acronyms” and throughout the text. Calculation of the composite uncertainty factor is consistent with current EPA dose-response assessment methodology as discussed in EPA's A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994).

Comment: A reviewer stated that “With a long half-life PFDA may accumulate in the body over time, that is, intake exceeds excretion from the body. Thus, a lifetime exposure may result in an internal exposure that is greater than in early life, if the rate of intake exceeds the excretion rate. I recommend that a calculation be completed in this regard using an animal/human PBPK model for PFDA to gain insights into subchronic and chronic exposures. If no accumulation appears likely (quasi-steady state) then justify your UF by giving examples of chemicals that have 28-day, 90-day and 2-year toxicity information. Is a UF of 10 justified?”

EPA Response: The pharmacokinetic portion of the UF_A_ is based on chemical-specific PK data in animals and humans (reducing the uncertainty as compared with default extrapolations), and the UFs was set to a value of 10 for interpretation of the rat 28-day studies to address the concern that continued exposure, even in the absence of accumulation, could lead to a larger effect due to pharmacodynamic factors.

As shown in Figure G-8, PK model predictions that are reasonably accurate indicate accumulation occurs throughout the 28-day NTP bioassay. The PK analysis now accounts for this accumulation in estimating the average concentration in rats during a 28-day study. The PK model is used to estimate the internal dose during the mouse developmental study, for which the estimated average concentration was also used, hence accounting for accumulation. There are no 90-day or 2-year animal toxicity studies being evaluated. The estimated human half-life of 4.7 years (see Table 3-3) indicates accumulation over a number of years for humans but not for an entire lifetime. The NHANES PFDA data in Figure 3-2 indicate only modest accumulation in individuals past their mid-twenties, so for human dosimetry calculations, the assumption of steady state is deemed appropriate. Since EPA has switched from use of the DDEF to use of the PK model or interpolation of measured serum concentrations (informed by the model) for evaluation of the dosimetry in rats and mice, the revised approach addresses the lack of accumulation in the animal toxicity studies, reducing the uncertainty in extrapolation to longer durations.

Comment: A reviewer stated that “I can see the rationale, more or less, for PFDA. I am stuck with the mixture issues and the uncertainty about PFDA potency when found in a mixture. I think the epidemiologic tools used to tease out its contribution need to be more transparent, using a language that all can understand.”

EPA Response: EPA details how this complex issue is addressed in the PFAS protocol (U.S. EPA, 2021b) and in Section 1.2.3: “The potential for confounding across PFAS is incorporated in individual study evaluations and assessed across studies in evidence synthesis. In most studies, it is difficult to determine the likelihood of confounding without considering additional information not typically included in individual study evaluation (e.g., associations of other PFAS with the outcome of interest and correlation profiles of PFAS within and across studies). In addition, even when this information is considered or the study authors perform analyses to adjust for other PFAS, it is often not possible to fully disentangle the associations due to high correlations. This stems from the potential for amplification bias in which bias can occur following adjustment of highly correlated PFAS (Weisskopf et al., 2018). Thus, in most studies, there may be some residual uncertainty about the risk of confounding by other PFAS. A “Good” rating for the confounding domain is reserved for situations in which concern is minimal for substantial confounding across PFAS as well as other sources of confounding. Examples of this situation include results for a PFAS that predominates in a population (such as a contamination event) or studies that demonstrate robust results following multi-PFAS adjustment, which would also indicate minimal concern for amplification bias. Because of the challenge in evaluating individual studies for confounding across PFAS, this issue is also assessed across studies during the evidence synthesis phase (as described in the systematic review protocol; Appendix A, Section 9), primarily when there is support for an association with adverse health effects in the epidemiological evidence (i.e., moderate or robust evidence in humans, as described below). Analyses used include comparing results across studies in populations with different PFAS exposure mixture profiles, considering results of multipollutant models when available, and examining strength of associations for other correlated PFAS. In situations in which there is considerable uncertainty regarding the impact of residual confounding across PFAS, it is captured as a factor that decreases the overall strength of evidence (see Appendix A.10).” In addition to the protocol text above, for each health effect with moderate or robust epidemiological evidence (i.e., developmental and immune), there is text within the synthesis (or an accompanying appendix) that describes how these considerations were applied for that health effect. The specific approach is driven by the available data for that health effect; analyses appropriate with several studies reporting multipollutant modeling results are not appropriate when few are available. Other sections (i.e., with slight or indeterminate synthesis judgments) do not include this thorough analysis because other sources of uncertainty (e.g., inconsistency) are more substantial and it would be difficult to identify patterns related to confounding across PFAS. Lastly, EPA provided an evaluation of the potential for confounding for studies of birth weight in Appendix F. This discusses the strengths and limitations of single and multipollutant modeling and provides details on any direct evidence for confounding by comparing modeling results and examining underlying relationships between co-occurring PFAS and this endpoint.

Comment: A reviewer stated that “The justification for a UF of 1 for a sensitive lifestage was not clear.”

EPA Response: The justification was revised as follows: “The developmental period is recognized as a susceptible lifestage when exposure during a time window of development is more relevant to the induction of developmental effects than lifetime exposure in adulthood.”

### H.4.4 Public Comments on Noncancer Toxicity Value Uncertainty Factors

Comment: A commenter stated “EPA asserts that the overall uncertainty in that extrapolation is less than a factor of 3, concluding that the choices involved in human clearance would offset the uncertainty of the rat dosimetry. This rationale is not clearly worded, but it appears that EPA means that the rat dosimetry would tend to result in overly high clearance rates, and that the choice to use a low fecal excretion rate in humans would offset this uncertainty. The value assumed for fecal clearance (73% of urinary clearance) is overly conservative, as noted by DOD. The review of excretion patterns in rats and humans demonstrates that fecal excretion is important for long-chain PFAS. Several sources cited in the draft report a greater proportion of excretion via the fecal route than via the urinary route for PFDA (Kudo et al.2001; Fujii et al. 2015; Kim et al. 2019). Selecting an unusually low value for fecal clearance to offset the high value of urinary clearance does not offset the uncertainty of the rat dosimetry; rather, the practice unnecessarily reduces the assumed clearance rates. Finally, it is unclear how EPA determined that the uncertainty associated with the animal-to-human extrapolation is within a factor of 3, unless EPA is asserting that fecal excretion rate has no uncertainty and thus does not contribute to the uncertainty associated with extrapolation.”

EPA Response: The fecal elimination estimate of Fujii relies on animal PK data (V_d_), read-across analysis from other PFAS, and data from only five human subjects, all being treated for diseases, hence is considered highly uncertain. However, based on comparisons of the results of Fujii to estimates of total versus urinary clearance of other PFAS (for which both types of estimates were available), it appears the fecal clearance estimates of Fujii are in the correct range. Therefore, the total human clearance estimate was revised to use the value for fecal clearance from Fujii.

Given the variability in the PK data and estimates, it is possible that human clearance is more than threefold higher than the value used. The estimated factor of 3 was for the possibility that clearance is lower than the value used, i.e., based on the data available, EPA considers it unlikely that the true human mean is more than threefold lower than the estimated value or that a significant part of the population has a clearance that much lower.

## H.5 CHARGE QUESTIONS 7 AND 8 – CARCINOGENICITY HAZARD IDENTIFICATION AND TOXICITY VALUE DERIVATION

7 The Toxicological Review concludes there is inadequate information to assess carcinogenic potential for PFDA and that this descriptor applies to oral and inhalation routes of human exposure. Please comment on whether the available human, animal, and mechanistic studies, and the analysis presented in the Toxicological Review are scientifically justified and clearly described.
8 Given the conclusion there was inadequate information to assess carcinogenic potential for PFDA, the Toxicological Review does not derive quantitative estimates for cancer effects for oral or inhalation exposures. Is this decision scientifically justified and clearly described?

### H.5.1 External Peer-Review Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

#### Peer-Review Comment Summary

In reference to charge question 7, eight reviewers agreed that there currently is inadequate information to assess the carcinogenetic potential of PFDA. However, one of the reviewers also commented on including elaboration about observations of chromosomal abnormalities and an additional reviewer agreed on these points (see below). One reviewer refrained from commenting.

In reference to charge question 8, all nine reviewers agreed that the decision not to derive quantitative estimates for cancer effects for oral or inhalation exposures was scientifically justified and clearly described.

#### Tier 1 Necessary Revisions

Comment: A reviewer identified an additional study by Pan et al., (2019) that reports on the association of PFDA exposure with DNA fragmentation in human sperm and stated, “A Tier 1 recommendation is given here to first determine where in the hazard identification process such DNA impacts will be reviewed and second to undertake the evaluation of such data for the additional endpoint. This reviewer would suggest to add to the supplemental information considered for reproductive impacts.”

EPA Response: As stated previously, Pan et al., (2019) reported an association with increased sperm DNA fragmentation; however, the results for semen parameters most relevant for evaluation of male reproductive effects (i.e., motility, concertation, and morphology) were null, inconsistent, or imprecise (nonsignificant). Therefore, EPA concluded that the study would not be included since it does not influence the assessment conclusions for human or mechanistic evidence or the overall hazard judgment for male reproductive effects. Text was added to Table I-1 in Appendix I to clarify EPA's disposition on the DNA fragmentation findings from the Pan et al., (2019) study.

#### Tier 2 Suggested Revisions

Comment: Another reviewer suggested, “To avoid readers confusing ‘inadequate information' with ‘not carcinogenic, ' recommend that values for PFASs with similar properties (e.g., PFOA and PFOS) be noted.”

EPA Response: Table 4-1 in the Toxicological Review draft compares hazard conclusions for PFDA and other PFAS (e.g., PFOS and PFOA) across published EPA human health assessments, including judgments for carcinogenicity, the latter of which includes descriptors based on EPA guidelines.

### H.5.2 Public Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

No public comments were provided.

## H.6 ADDITIONAL COMMENTS

### H.6.1 Additional External Peer-Review Comments

#### Tier 1 Necessary Revisions

Comment: A reviewer recommended “Check Table 1-1 for consistency with information currently available on online (on portals such as EPA's CompTox Chemicals Dashboard); evaluate the feasibility of expanding Table 1-1 by including values of PFDA properties that are critical for is pharmacokinetics (e.g., binding affinities to serum proteins).”

EPA Response: The physical-chemical properties listed in Table 1-1 have been updated on the basis of values from the U.S. EPA CompTox Chemicals Dashboard as of January 17, 2024. The list of properties presented in Table 1-1 is boilerplate; property values related to pharmacokinetics can be found in Section 3.

Comment: A reviewer noted that the toxicological effects of PFDA are best addressed from a mixtures perspective, since it appears unlikely that the effects of PFDA, which represents only a few percent of the total mixture, can be teased out for regulatory purposes. A section on mixtures could be added to the assessment. Additionally, the language on confounding across PFAS for epidemiological studies (page 1–11 and 1–12) under the Summary of Assessment Methods is inadequate and the strengths and weaknesses of such assumptions should be clearly articulated in nonepidemiological language.

EPA Response: This Toxicological Review is specific to PFDA and its related salts and the consideration of a potential additive effect of exposure to multiple PFAS chemicals would not be appropriate for a scientific document developed for one PFAS. The consideration of potential additive effects of exposure to multiple PFAS would be part of the risk assessment and risk management activities such as the application of this Toxicological Review (once finalized), along with other relevant assessments by risk managers addressing human exposure to multiple PFAS. Thus, this is outside of the scope of the IRIS Program. The draft human health toxicity values for PFDA are part of a broader PFAS strategic roadmap (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021-2024 and the environment from PFAS contamination. Text was added to the Executive Summary of the Toxicological Review draft to provide examples from the PFAS strategic roadmap aimed at evaluating health effects from individual PFAS and PFAS mixtures or groups. Additionally, Table 4-1 in Section 4.1 compares health effects for PFDA and other PFAS across EPA human health assessments, highlighting notable data gaps for PFDA and PFAS in general.

#### Tier 2 Suggested Revisions

Comment: A reviewer suggested “With the limited number of studies on PFDA some mention of the location of summary charts with all PFAS effects showing a comparison across all PFAS would be useful.”

EPA Response: Table 4-1 compares hazard conclusions for PFDA and other PFAS across EPA human health assessments, highlighting major data gaps for PFDA and PFAS in general.

Comment: A reviewer commented, “A Tier 2 recommendation is for the authors to add an explanatory paragraph that states how the Computational Toxicology information, now primarily in the appendix, is or will be incorporated across endpoints and effects. Such a paragraph is needed to ensure the intended user of the current IRIS review is clear and can articulate how and when the additional information from the appendix was used and also perhaps when it was not used across endpoints.”

EPA Response: Section 1.2.5 of the Toxicological Review discusses the approach for synthesizing mechanistic evidence including computational toxicology data, and more details can be found in the systematic review protocol for the PFAS Toxicological Reviews (see Appendix A, Section 9.2). Evaluation of computational toxicology data involved targeted analyses that were considered helpful to inform key decisions regarding the human and animal evidence. For example, available in vitro high-throughput screening assays from the ToxCast/Tox21 databases were compiled and analyzed to address questions of biological plausibility and human relevance of PFDA-induced liver and reproductive effects.

Comment: Three reviewers identified several references for consideration related to human and animal pharmacokinetics, in vitro and in silico studies, human exposure, human population health effects, large-scale biomonitoring programs, review articles, risk assessments, frameworks and protocols for PFDA and/other PFAS.

EPA Response: EPA has reviewed these references against the PECO criteria. Tables I-1, I-2 and I-3 in Appendix I provide the identified studies that met PECO criteria or certain supplemental evidence categories (i.e., in vivo mechanistic or MOA studies, including non-PECO routes of exposure and populations; in vitro and in silico models; and ADME and pharmacokinetic studies) and EPA's judgment on whether the studies would have a material impact on the assessment conclusions (i.e., identified hazards or toxicity values). Three ADME-related studies identified by the reviewers were incorporated into the pharmacokinetics section (see Section 3.1) of the Toxicological Review because they help address specific data gaps (Bao et al., 2022; Chen et al., 2022; Perez et al., 2013). The results of this screening are also included on the HERO project page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2614).

### H.6.2 Additional Public Comments

Comment: One commenter noted “Given that people are exposed to PFAS mixtures and PFDA causes similar health effects at similar doses as other PFAS, EPA should consider including a section on PFAS cumulative risks.

EPA Response: This Toxicological Review is specific to PFDA and its related salts, and the consideration of a potential additive effect of exposure to multiple PFAS chemicals would not be appropriate for a scientific document developed for one PFAS. The consideration of potential additive effects of exposure to multiple PFAS would be part of the risk assessment and risk management activities such as the application of this assessment (once finalized) along with other relevant assessments by risk managers addressing human exposure to multiple PFAS. Thus, this is outside of the scope of the IRIS Program. The draft human health toxicity values for PFDA are part of a broader PFAS strategic roadmap (https://www.epa.gov/pfas/pfas-strategic-roadmap-epas-commitments-action-2021–2024) at EPA for protecting human health and the environment from PFAS contamination. Text was added to the Executive Summary of the Toxicological Review draft to provide examples from the PFAS strategic roadmap aimed at evaluating health effects from individual PFAS and PFAS mixtures or groups. Additionally, Table 4-1 in Section 4.1 compares health effects for PFDA and other PFAS across EPA human health assessments, highlighting notable data gaps for PFDA and PFAS in general.

7 The Toxicological Review provides an overview of individual study evaluations within each evidence synthesis section, and the results of those outcome-specific evaluations are made available in the Health Assessment Workplace Collaborative (HAWC (https://hawc.epa.gov/assessment/100500072/)). Note that a HAWC Frequent Questions page, linked here (https://www.epa.gov/risk/hawc-frequent-questions), is available to help the reviewer navigate this online resource.

8 For the decreased antibody responses, Selgrade (Tox Sci 2007;100:328–332) suggests these specific immunotoxic effects may be broadly indicative of developmental immunosuppression impacting these children’s ability to protect against a range of immune hazards. For developmental effects (i.e., fetal growth restriction), the human evidence was determined to be slight, primarily due to potential confounding by hemodynamic changes among studies showing birth weight deficits. For the study (i.e., Wikström, 2020), used to derive the developmental RfD, there is no presumed impact of pregnancy hemodynamics given the early sampling (96% from the first trimester). However, unlike the Wikstrom (2020) study, some uncertainty remains across many of the available human developmental studies given the predominance of associations that were detected were for studies with later pregnancy sampling.