# APPENDIX G DETAILED PHARMACOKINETIC ANALYSES

This appendix provides two detailed pharmacokinetic analyses. The first is a Bayesian analysis of perfluorodecanoic acid (PFDA) pharmacokinetics in laboratory animals to estimate key pharmacokinetic (PK) parameters. The second is the description and evaluation of a one-compartment PK modeling approach for estimating internal doses, evaluated against rat PFDA PK data using the mean parameter values estimated for male rats in the Bayesian estimation.

## G.1 PARTIAL POOLING OF PFDA PHARMACOKINETIC DATA FOR HIERARCHICAL BAYESIAN ANALYSIS

We estimated the sex-specific pharmacokinetic parameters (half-life, volume of distribution, and clearance) of PFDA in rats by fitting one- and two-compartment models to the available concentration-versus-time data. A Bayesian hierarchical methodology was developed to fit these models because of the need to pool time-course concentration data across numerous studies with varying exposure scenarios within each study. This allowed for each concentration-versus-time dataset to be fit to each pharmacokinetic model for which fitted parameters for each dataset are sampled from a population-level distribution, which models the similarities between each dataset. In addition, the Bayesian analysis allowed for the generation of central estimates and credible intervals for the PK parameter of interest, e.g., half-life, volume of distribution and clearance, using posterior distributions from the estimated variables. Finally, the Bayesian methodology allowed for hypothesis testing of the one- and two-compartment formulations to decide which model more appropriately fit the data.

### G.1.1 Pharmacokinetic Model

To determine pharmacokinetic parameters for PFDA, we estimated constants for both one- and two-compartment model assumptions. For a one-compartment model assumption, the following exponential decay functions were fit to the available data:

C_1 - c m p t_^I V^ ( t ) = (D)/(V) e^- k_e_ t^ G-1

C_1 - c m p t_^o r a l^ ( t ) = (D)/(V) ((k_a_)/(k_a_ - k_e_)) (e^- k_e_ t^ - e^- k_a_ t^) G-2

where D represents the administered dose and V, K_e_, and K_a_ represent the central compartment volume, elimination constant, and absorption constant (for oral only) to be fit. From these fitted constants, pharmacokinetic parameters are derived:

V_d_ = (V)/(B W) G-3

t_½_ = (l n 2)/(k_e_) G-4

C L C = V_d_ * k_e_ G-5

where V_d_, t_1/2_, and CLC represent the volume of distribution, terminal half-life, and clearance, respectively, and BW represents the animal body weight.

For the two-compartment model assumption, the following exponential decay functions were fit to available data

A^I V^ = (α - k_d c_)/(α - β) ; A^oral^ = k_a_ ((k_d c_ - α)/((k_a_ - α) ( β - α ))) G-6

B^I V^ = (β - k_d c_)/(β - α) ; B^oral^ = k_a_ ((k_d c_ - β)/((k_a_ - β) ( α - β ))) G-7

C_2 - c m p t_^I V^ ( t ) = (D)/(V) (A^I V^ e^- α t^ + B^I V^ e^- β t^) G-8

C_2 - c m p t_^oral^ ( t ) = (D)/(V) (A^oral^ e^- a t^ + B^oral^ e^- β t^ - (A^oral^ + B^oral^) e^- k_a_ t^) G-9

where D represents the administered dose and V, α, β, k_dc_, and k_a_ represent central compartment volume, alpha-phase elimination constant, beta-phase elimination constant, deep-to-central compartment rate constant, and absorption constant (for oral only) to be fit. From these fitted constants, the remaining two-compartment constants (k_cd_: central-to-deep compartment rate constant and k_e_: elimination constant) and the deep compartment volume (V_deep_) are derived by solving:

α + β = k_c d_ + k_d c_ + k_e_ G-10

α * β = k_d c_ * k_e_ G-11

V_d_ = V (k_c d_)/(k_d c_) G-12

which allows for the desired pharmacokinetic parameters to be derived using the following equations:

V_d - s s_ = (V + V_d e e p_)/(B W) = (V)/(B W) ((k_c d_ + k_d c_)/(k_d c_)) G-13

t_1 / 2_ = (l n 2)/(β) G-14

C L C = (V)/(B W) * k_e_ G-15

where V_d–ss_, t_1/2_, and CLC represent the steady-state volume of distribution, terminal half-life, and clearance, respectively, and BW represents the animal body weight.

### G.1.2 Bayesian Inference

The fitted constants for each model structure (described above) were estimated using available time-course concentration data reported in rats with parameters for each model estimated using a hierarchical Bayesian calibration approach. This hierarchical Bayesian approach pooled the time-course concentration data for male and female rats from multiple studies Ohmori et al. (2003), Kim et al. (2019), Dzierlenga et al. (2019). For the two-compartment model, to ensure parameter identifiability, α and β were constrained to be ordered such that α > β. This constraint ensures the exponential terms are identifiable and do not “flip” while exploring the parameter space during Markov-chain Monte-Carlo (MCMC) sampling. Finally, priors for each pharmacokinetic parameter were chosen to be “weakly informative" on the basis of prior knowledge of PFAS pharmacokinetics (ATSDR, 2021) with 95% equal-tailed intervals spanning multiple orders of magnitude.

Priors for pharmacokinetic parameters are presented in Table G-1 with corresponding model-specific parameter prior distributions presented below. Finally, a sensitivity analysis on the model priors is shown in Section G.1.3.

Table G-1 Weakly informed prior distributions for pharmacokinetic parameters used in the Bayesian analysis

| median | mad | eti_3% | eti_97%
Half-life (d) | 15 | 12 | 0.88 | 250
Clearance (mL/kg-d) | 50 | 49 | 0.32 | 6, 000
V_d−ss_ (mL/kg) | 900 | 811 | 9.3 | 32, 822

For the hierarchical approach, the concentration-versus-time data comprised a population level and dataset level for which model parameters were estimated. Here, each dataset represented each study/sex/dose concentration-versus-time dataset extracted from the literature and were fit using the model.

C_i j_ = {C_1 - cmpt_^route^ for 1-compartment model C_2 - c m p t_^route^ for 2-compartment model G-16

C_i k_ ∼ L N (x‾_i j_ , σ˜_k_) G-17

where x‾_i j_ is the sample mean of the observed concentrations at time t_ij_ for dataset j, and σ˜_k_ is the study-level log-transformed standard deviation for the relative errors based on study k. Study-level priors for σ˜_k_ were determined using the average log-transformed standard deviations.

σ‾_i , j_^2^ = l n (1 + (s_i , j_^2^)/(x‾_i , j_^2^)) G-18

γ_k_ = (∑_i_ σ‾_i , j ∈ k_)/(n_k_) G-19

where s_i, j_ is the sample standard deviation on the observed concentrations at time t_i, j_ for study k. If s_ij_ was available, σ‾_i , j_ is the log-transformed standard deviation using the sample mean and standard deviation. For studies from which sample standard deviations could not be extracted, an average of all log-transformed standard deviations was used. This allowed for study-level prior distributions on the error model log-transformed standard deviation:

σ˜_k_ ∼ {E x p (1 / γ_k_) if γ_k_ available E x p ( 1 / γ ) otherwise. G-20

Using this model, dataset-level fitted constants were assigned priors on the basis of a noncentered parameterization of a population-level distribution. This reparameterization of a typical hierarchical Bayesian model allows for increased sampling efficiency and can be more efficient for sampling when there is limited data (Betancourt and Girolami, 2013). Finally, nonelimination rate constants (k_a_ and k_dc_) were assigned a unit normal, weakly informative prior to aid parameter identifiability (Gelman et al., 2015).

l n μ_k_a__ ∼ N ( 0, 1 ) G-21

l n μ_V_ ∼ N ( 0, 1 ) G-22

l n μ_k_e__ ∼ N ( - 3, 1.5 ) o n e c o m p a r t m e n t m o d e l G-23

l n μ_k_d c__ ∼ N ( 0, 1 ) t w o c o m p a r t m e n t m o d e l G-24

l n μ_a_i_ β_ ∼ N ( - 3, 1.5 ) , μ_β_ < μ_α_ t w o c o m p a r t m e n t m o d e l G-25

σ_k_α_ , V , k_e_ α , β , β , k_d c__ ∼ E x p ( 3 ) G-26

l n (k_a_ , V , k_ε_ , α , β , k_d c_)_j_ ∼ N (μ_k_a_ , V , k_e_ , α , β , k_d c__ , σ_k_α_ , V , k_e_ , α , β , k_d c__) G-27

One- and two-compartment model goodness of fits were compared using the widely applicable information criteria (WAIC). Pharmacokinetic parameters from the most appropriate model, as judged by the WAIC comparison, were reported. To estimate the population-level pharmacokinetic parameters, we examined posterior probability densities of the parameters from the WAIC-determined model and calculated distributional estimates of the half-life, volume of distribution, and clearance using the equations described above. The parameter space was sampled using PyMC (Salvatier et al., 2016) using four independent Markov chains run for 10, 000 iterations per chain. Posterior parameter distributions were determined using the final 5, 000 iterations of each chain ensuring an effective sample size (ESS) greater than 10, 000 (Kruschke, 2021). Convergence was assessed using a potential scale reduction factor with a maximum threshold of R = 1.05 (Kruschke, 2021).

### G.1.3 Prior Sensitivity Analysis

To investigate the impact of prior selection on posterior pharmacokinetic parameter estimation, we conducted a sensitivity analysis on the priors used in the Bayesian analysis. Priors were classified into three categories: weakly informed, broad, and uninformed. Weakly informed priors are defined using the half-life, clearance, and volume of distribution, described above on the basis of reported ranges of PFDA pharmacokinetics with a prior predictive check demonstrating available data for fitting fall within the prior 90% credible interval (see Figure G-1).

Figure G-1 Prior predictive check to ensure equal-tailed interval from prior distributions encompass the available time-course concentration data for fitting.

Figure G-1. Prior predictive check to ensure equal-tailed interval from prior distributions encompass the available time-course concentration data for fitting.

In addition to these weakly informed priors, we also characterized a set of broad priors, defined as uniform distributions spanning the 3% and 97% equal tailed interval (ETI, analogous to corresponding percentiles) from the weakly informed priors, and completely uninformed priors, representing uniform priors spanning multiple orders of magnitude (i.e., flat priors). Figure G-2 (prior sensitivity) compares these three classes of priors and their impact on the posterior pharmacokinetic parameter distributions,

Figure G-2 Prior sensitivity on half-life, steady-state volume of distribution, and clearance to ensure weakly informed priors do not bias posterior distributions of the pharmacokinetic parameters.

Figure G-2. Prior sensitivity on half-life, steady-state volume of distribution, and clearance to ensure weakly informed priors do not bias posterior distributions of the pharmacokinetic parameters.

Based on these findings, we used the weakly informed pharmacokinetic priors for fitting available time-course concentration data.

### G.1.4 Study-Specific Clearance Values and Model Fits

Three datasets were used for the sex-specific parameter estimation, which had a mixture of gavage and i.v. exposure routes and follow-up times extending up to 150 days (Dzierlenga et al., 2019; Kim et al., 2019; Ohmori et al., 2003). The sex-specific clearance value distribution obtained from fitting the three datasets together had a mean and 90% credible interval of 4.06 (2.05–6.05) mL/kg-day in female rats and 4.14 (0.68–7.02) mL/kg-day in male rats. For these data, a two-compartment PK model was deemed superior. Visual inspection shows some of the data have a distinguishable distribution and excretion phase, which is appropriate for a two-compartment model (see Figure G-3). A two-compartment model can fit data that appear linear as is evidenced in fits to other datasets (see Figure G-4). Credible intervals for the fits to individual datasets are qualitatively small showing good model fits to the data from individual studies. The relatively large credible interval for the pooled data is due to the large variation between studies. For example, in male rats the mean clearance values for individual studies ranged from 1.51 to 7.45 mL/kg-day, with a similar range in female rats.

Trends comparing the terminal clearance following i.v. and gavage doses appeared within studies but did not hold for the whole dataset. For example, in Kim et al. (2019) i.v. doses resulted in smaller, but similar clearance to gavage doses (see Figure G-4). However, these clearance values were consistently smaller than clearance values calculated from the two other datasets. In the analysis of the Dzierlenga et al. (2019) dataset, i.v. doses resulted in clearly greater clearance than the three dose levels administered by gavage, which all had similar clearance within each sex (see Figures G-5 and G-6). There was a difference in clearance between sexes in this study, but only for gavage doses. In this study, the gavage doses resulted in mean clearance values between 3.57 and 3.77 mL/kg-day in female rats and 5.12 and 5.74 mL/kg-day in male rats. However, the clearance calculated from the single i.v. dose was similar between female and male rats. Likewise, the two other studies showed similar mean clearance values for male and female rats (see Figure G-3 and Figure G-4). That most of the difference in PFDA PK between male and female rats is related to a difference in absorption, which can be moderated by active transport, is possible. Additional experiments designed to carefully evaluate these factors would be needed to resolve this question.

Figure G-3 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female (left) and male (right) rats after a 25 mg/kg i.v. bolus of PFDA.

Observed data from (Ohmori et al., 2003).

Figure G-3. Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female (left) and male (right) rats after a 25 mg/kg i.v. bolus of PFDA. Observed data from (Ohmori et al., 2003).

Figure G-4 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female (top 2 panels) and male (bottom 2 panels) rats after a 1 mg/kg gavage or i.v. bolus of PFDA.

Gavage exposures are on the left, and i.v. exposures are on the right. Observed data from (Kim et al., 2019).

Figure G-4. Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female (top 2 panels) and male (bottom 2 panels) rats after a 1 mg/kg gavage or i.v. bolus of PFDA. Gavage exposures are on the left, and i.v. exposures are on the right. Observed data from (Kim et al., 2019).

Figure G-5 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female rats after a 2 mg/kg i.v. or 2,10, or 20 mg/kg gavage bolus of PFDA.

Observed data from (Dzierlenga et al., 2019).

Figure G-5. Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for female rats after a 2 mg/kg i.v. or 2,10, or 20 mg/kg gavage bolus of PFDA. Observed data from (Dzierlenga et al., 2019).

Figure G-6 Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male rats after a 2 mg/kg i.v. or 2,10, or 20 mg/kg gavage bolus of PFDA.

Observed data from (Dzierlenga et al., 2019).

Figure G-6. Predicted (black line with blue 90% credible interval) and observed (black circles) serum time-courses for male rats after a 2 mg/kg i.v. or 2,10, or 20 mg/kg gavage bolus of PFDA. Observed data from (Dzierlenga et al., 2019).

## G.2 DESCRIPTION AND EVALUATION OF A TWO-COMPARTMENT PK APPROACH FOR ESTIMATION OF INTERNAL DOSES IN RATS

For PFDA, the clearance values obtained in the preceding Bayesian analysis are low enough that internal doses will not reach steady-state for shorter-term studies, in particular for the rat NTP 28-day bioassay. In this case a PK model could be used to account for the growth of the animal, the intrinsic elimination, and the accumulation of PFDA over the period of dosing. The two-compartment PK model is given by:

d A_c_ / d t = F_a b s_ × dose × B W - C L_t o t_ × A_c_ / V_c_ - k_12_ × A_c_ + k_21_ × A_t_ and G-29

d A_t_ / d t = k_12_ × A_c_ - k_21_ × A_t_ , G-30

where A_c_ and A_t_ are the total amounts of PFDA in the animal's central (c) and tissue (t) compartments (mg), F_abs_ is the fraction absorbed for an oral dose (bioavailability), BW is the body weight (kg), CL_tot_ is the total clearance (L/kg-d), V_c_ is the volume of distribution for the central compartment (L/kg), and k_12_ and k_21_ are the rate constants for transfer from the central to tissue and tissue to central compartments, respectively (d^−1^). The concentration in plasma (central compartment) is:

C_p l a s m a_ = A_c_ / (V_c_ × B W) . G-31

The differential equation for the amount of chemical in the central compartment can then be rewritten:

d A_c_ / d t = F_a b s_ × dose × B W - C L_t o t_ × B W × C_p l a s m a_ - k_12_ × A_c_ + k_21_ × A_t_ , G-3

which leads to the interpretation that the volume of plasma cleared of the chemical per unit time per kg BW is CL_tot_.

Computational model code to implement this PK model for the specific analyses described below is available from (Schlosser, 2024).

PK parameters for male and female rats (F_abs_, CL_tot_, k_12_, k_21_, and V_c_) were taken from the preceding Bayesian analysis. Specifically, samples containing 1000 parameter sets from the posterior distribution of the Bayesian analysis for the population-level parameters for male and female rats were used for subsequent analysis. The algebraic mean of each parameter from the sex-specific sample was calculated independently from each sample to generate model predictions for an average male or female rat, respectively. Given the slow clearance of PFDA, the growth of rats during toxicity studies lasting multiple weeks can be a significant factor as increases in BW dilute the body burden from earlier exposures. The highest doses tested in the NTP bioassay significantly reduced animal BW, which compounds this effect. Therefore, time-dependence in BW based on the empirical data for BW at the doses evaluated was incorporated into the model evaluation, to account for this time dependence and dose dependence. For illustration, the change in male rat BW observed in the NTP bioassay (28-day exposure (NTP, 2018)) is shown in Figure G-7. Doses of 0.625 mg/kg-day and below did not significantly affect BW gain during the bioassay, but higher dose levels caused a significant decline after 7 days of exposure.

### G.2.1 Evaluation of the Two-Compartment PK Model Predictions for Rats

The internal dose of PFDA predicted by the PK model as a function of exposure day, normalized to the dose for comparison, is shown in Figure G-8. For example, the model simulated concentrations obtained using a dose of 0.625 mg/kg-day were divided by 0.625 before plotting. If the BW curve was the same for all doses, all the resulting normalized curves would be superimposed. The predicted concentration increases steadily throughout the study for all dose levels, showing no sign of saturation. However, the increase in animals receiving the highest doses becomes relatively faster after day 7, deflecting above the lower-dose curves. This occurs because the decreasing BW at these doses concentrates the PFDA already administered into a smaller total animal mass. For model simulations, the dose is assumed to be adjusted continuously on the basis of the time-interpolated weights as shown in Figure G-7. (The study report states that animals were weighed daily, but only weekly values are provided there.) For example, if an animal loses weight between day 7 and day 21, the daily dose is assumed to be adjusted accordingly. Since the animals were necropsied on day 29, 1 day after the final dose, the model simulations include a final day with zero exposure. Mean (±SD) serum PFDA concentrations from the NTP study, collected at time of necropsy, are shown for comparison.

Figure G-7 Male rat body weight changes during 28-day PFDA bioassay (NTP, 2018).

Datasets are identified by the dose (mg/kg-d).

Figure G-7. Male rat body weight changes during 28-day PFDA bioassay (NTP, 2018). Datasets are identified by the dose (mg/kg-d).

Figure G-8 Predicted accumulation and observed end-of-study of PFDA in male and female rats in the NTP bioassay (NTP, 2018) as a function of study day.

Predicted and measured concentrations (mg/L) were normalized to respective doses (mg/kg-d). Data are mean ± SD, jiggered from day 29 (when samples were collected) to make error bars distinct.

Figure G-8. Predicted accumulation and observed end-of-study of PFDA in male and female rats in the NTP bioassay (NTP, 2018) as a function of study day. Predicted and measured concentrations (mg/L) were normalized to respective doses (mg/kg-d). Data are mean ± SD, jiggered from day 29 (when samples were collected) to make error bars distinct.

In Figure G-8 the model consistently underpredicts the male rat data by 15%-40% and, while the prediction for the lowest dose is within 1 SD of the mean, the predictions for higher doses are 30%-40% below the mean with more than 1SD difference. The results for female rats are considerably better, no more than 22% below the mean measured levels and three of the five predictions are within 1 SD. While EPA generally considers this much discrepancy acceptable for a comparison of PK model predictions to data, that there is systematic bias rather than some predictions being above and some below the data raises concern. One might also note the data point for 0.625 mg/kg-day is less than that for 0.312 mg/kg-day, whereas the model simulations show only increasing normalized concentration with dose. For male rats there is a greater overall effect of dose in the data (distance between lowest and highest point) than that predicted by the model, although for female rats the model performs well in this regard. To further evaluate the extent of nonlinearity, the end-of-study plasma concentrations from NTP (2018), PK-model-estimated concentrations, and the estimated steady-state concentration (dose/clearance) are plotted against the dose in Figure G-9. The exposure-dose relationship is essentially linear for the three lowest doses (to 0.625 mg/kg-day), with some variation, and then increases a bit more rapidly than linearly with dose above that. As indicated by the BW data in Figure G-7 and resulting simulations in Figure G-8, this upward inflection could be due to dose-related BW losses, which are assumed to concentrate the previously administered PFDA into a smaller total volume. While this assumption is incorporated into PK model, the model systematically underpredicts the mean concentration at the end of the study, even at the lowest dose. This under-prediction of the PK data suggests that a secondary factor, not incorporated into the model, is involved. The PK model also incorporates the assumption that the distribution of PFDA to body tissues (ratio of amount in tissues vs. serum) is constant, but the data suggest less distribution at the end of the study than estimated from single-dose PK studies. If the growing rats, especially the males, have a disproportionate increase in volumes of tissues in which PFDA distributes poorly, such as fat, the overall volume of distribution will decrease over time, resulting in higher than predicted serum levels. This type of shift would require a valid PBPK model in which growth of specific tissue types is not assumed to be directly proportional to total body weight.

Also, from Figure G-8, there is no evidence of saturation of renal resorption, which would result in downward curvature in the exposure-dose relationship (at higher doses). Instead, the discrepancy between the NTP data and the model simulations can be explained if clearance is somewhat lower than estimated from the PK studies or as suggested above, the volume of distribution decreases with growth of the rats over the 28 days.

Figure G-9 Measured end-of-study of PFDA in male and female rats in the NTP bioassay (NTP, 2018) as a function of dose versus model predictions.

Points are mean ± SD serum concentrations measured at the end of the bioassay (NTP, 2018). Gray lines are results from the PK model using 1, 000 posterior parameter samples from the Bayesian analysis (see Appendix G.1). Solid black lines are 5th and 95th percentiles of the samples. Dashed line is the steady-state serum concentration, i.e., dose/clearance.

Figure G-9. Measured end-of-study of PFDA in male and female rats in the NTP bioassay (NTP, 2018) as a function of dose versus model predictions. Points are mean ± SD serum concentrations measured at the end of the bioassay (NTP, 2018). Gray lines are results from the PK model using 1, 000 posterior parameter samples from the Bayesian analysis (see Appendix G.1). Solid black lines are 5th and 95th percentiles of the samples. Dashed line is the steady-state serum concentration, i.e., dose/clearance.

### G.2.2 Alternate Approach for PFDA PK Evaluation of Rats – Data Interpolation

As shown in Figures G-8 and G-9 and discussed above, the two-compartment PK model does a generally good job of predicting the serum concentrations observed in the NTP bioassay but has a systematic bias, consistently underpredicting the observed mean concentrations. However, the qualitative shape of the model prediction suggests an alternative approach for estimating the average concentrations from the measured serum concentrations. In particular, due to the low clearance in both male and female rats, the PK model predicts an almost linear increase in serum concentration with time during the bioassay and that the observed concentrations could be accurately predicted with only a small change in the parameters. One can expect, then, a more accurate model would also predict an essentially linear increase in concentration with time, but one that increases with a slope sufficient to match the observed means. If in fact the serum concentration increases linearly over the study duration, the average concentration during the study will simply be 50% of the final observed concentration. Further, given the near linearity in the exposure-dose relationship (see Figure G-9), one could reasonably estimate the final concentration for other doses (e.g., PODs identified from EPA's dose-response analyses) by linear interpolation between the two nearest reported concentrations. The resulting values are informed by the PK model results while using the observed concentrations, which likely reflect mechanisms not included in the PK model.

While Frawley et al. (2018) did not measure and report end-of-study serum concentrations from their toxicity study, they used the same strain of rats, study duration, and dosing and sacrifice schedule as (NTP, 2018). Therefore, the average serum levels will be imputed from the NTP end-of-study serum concentrations in the same way, using the serum concentrations reported in (NTP, 2018).

A computational script implement that performs the internal dose interpolation described here is contained in the model package available from (Schlosser, 2024).

### G.2.3 PK Evaluation for Gestational Exposure to PFDA in Mice

A toxicity POD was also determined for decreased fetal body weight in mice, reported by Harris and Birnbaum (1989). However, PFDA serum concentrations were not measured as part of this study so interpolation such as was done with the rat NTP data is not possible. Further, no gestational PK data are available for PFDA in mice or rats that might otherwise be used to evaluate model extrapolation to that lifestage, leading to high uncertainty for use of the PK model. Also noted is that the POD for this endpoint, 1 mg/kg-d, is high enough that the result is not a sensitive or critical observation. Therefore, the POD is extrapolated to humans using the data-derived extrapolation factor (DDEF) approach, i.e., POD_HED_ = POD_A_ × (F_abs, A_/F_abs, H_) × CL_H_/CL_A_. This follows from the PK prediction that given exposure to POD_A_, the serum concentration in the animal at steady-state is C_S, A_ = POD_A_ × F_abS, A_/CL_A_ and the human equivalent dose occurs when C_S, H_ = POD_HED_ × F_abs, H_/CL_H_ = C_S, A_, i.e., when humans have the same serum concentration as the animal.

Hence, POD_HED_ = C_S, A_ × CL_H_/F_abs, H_ = (POD_A_ × F_abs, A_/CL_A_) × CL_H_. In this case, CLA is set to the CL for female mice (2.2 mL/kg-d, (Fujii et al., 2015)), because dosimetry in the dam is what determines exposure to the mouse fetus. As discussed in Section 3.1.1, F_abs_ is estimated to be 100% for mice from the available data and is assumed to be 100% in humans given the lack of data to the contrary. In conjunction with UF_H_ = 0.147 mL/kg-d (see Table 3-3), the resulting POD_HED_ = (1 mg/kg-d)*(0.147 mL/kg-d)/(2.2 mL/kg-d) = 0.067 mg/kg-d.