# APPENDIX F ADDITIONAL CONFOUNDING CONSIDERATIONS

## F.1 SPECIFIC PFAS CONFOUNDING CONSIDERATIONS FOR FETAL GROWTH RESTRICTION

As noted in the PFAS protocol, the potential for bias in effect estimates due to confounding is a source of uncertainty in epidemiological studies and was a focus during study evaluation and as part of the overall weight-of-evidence determination. Hemodynamic changes occur during pregnancy, such as increased blood plasma volume as a result of decreased mean arterial pressure, increased cardiac output, and systemic vasodilation (Sagiv et al., 2018; Sanghavi and Rutherford, 2014; Chapman et al., 1998). These changes could lead to lower PFAS levels in plasma, due to dilution and increased renal filtration. In line with this, several studies have noted decreasing serum or plasma concentrations for many slowly cleared PFAS during pregnancy, although this finding is not consistent for perfluorodecanoic acid (PFDA) (Oh et al., 2022a; Chen et al., 2021; Mamsen et al., 2019; Pan et al., 2017; Glynn et al., 2012). One study, however, noted an increase in serum concentration with pregnancy, suggesting either an increase in exposure to some PFAS during pregnancy or gestational changes in pharmacokinetics (e.g., decreased renal clearance) that are unique to this cohort (Taibl et al., 2023). These hemodynamic changes have been proposed as a potential confounder for associations between PFDA and neonatal and early childhood growth measures. This is suggested by the association between glomerular filtration rate (GFR), a marker of renal function and, indirectly, of plasma volume expansion, and fetal growth independent of gestational age and other maternal covariates (Morken et al., 2014; Gibson, 1973). Because PFDA concentration in serum is expected to decrease during pregnancy due to plasma volume expansion, increased renal excretion, and transplacental transfer, time windows earlier in pregnancy prior to this decrease may reflect the largest insult to a developing fetus. Potential confounding is one possible explanation for the effects of pregnancy hemodynamics, but in their meta-analysis of PFOA, Steenland et al. (2018) also proposed that GFR may lead to reverse causality if increased fetal growth leads to increased maternal blood expansion and glomerular filtration rate. This potential source of bias related to pregnancy hemodynamics is anticipated to be of greater concern when maternal serum PFAS samples are collected later in pregnancy. Therefore, as part of the study quality evaluations, more confidence was placed in studies that adjusted for different pregnancy hemodynamic markers or if they considered this potential source of confounding by sampling PFAS levels earlier in pregnancy. In an attempt to address this uncertainty, a few studies also adjusted for sample timing in their regression models. As noted in the syntheses, pattern analyses of study results were also considered according to biomarker sampling timing to determine if pregnancy hemodynamics may be a source of between-study heterogeneity.

Only 1 of the 22 PFDA birth weight-related studies included in the discussion on developmental effects in Section 5.2.1 of the Toxicological Review collected and analyzed maternal hemodynamic data such as GFR and/or albumin (i.e., a marker of plasma volume expansion). Gyllenhammar et al. (2018) did not find any evidence of confounding following statistical adjustment of different GFR measures for any of the PFAS examined. Except for one study that showed some differences in PFOA results following adjustment for albumin, the Gyllenhammar et al. (2018) results are consistent with a lack of confounding demonstrated by either adjustment for albumin (Sagiv et al., 2018) or different GFR measures (Manzano-Salgado et al., 2017; Whitworth et al., 2012) for different PFAS examined in other studies. Nonetheless, existing meta-analyses for both PFOA (Steenland et al., 2018) and PFOS (Dzierlenga et al., 2020) only detected birth weight deficits for later trimester sampling (e.g., beyond the first trimester). A more recent meta-analysis of PFNA (Wright et al., 2023) reported nonmonotonic differences for early, late, and postpartum biomarkers, but these results were all statistically significant irrespective of sample timing windows examined. One limitation of the earlier two meta-analyses is they had no ability to differentiate late pregnancy from postpartum measures. Only 5 of the 22 PFDA studies of mean birth weight in the overall population examined any first trimester measures, which precluded a more detailed examination here. But there was some qualitative evidence of sample timing differences for the birth weight findings in the overall population. For example, 9 of the 11 studies reporting birth weight deficits had biomarkers based on later sampling during or after pregnancy. The patterns by sample timing were not consistent across endpoints, but the evidence of larger birth weight associations with later sample timing for PFDA measures may be indicative of potential impacts of pregnancy hemodynamics. However, the ability to more fully evaluate this was limited given the available data and disparate exposure measures, distributions, and contrasts examined across studies. Future research is needed to further elucidate these complexities, especially in studies with early samples and/or with repeated measures during different stages of pregnancy.

## F.2 PFAS COEXPOSURE STATISTICAL APPROACHES AND CONFOUNDING DIRECTIONALITY

In general, an additional source of uncertainty in epidemiological studies is the potential for confounding by other PFAS (and other co-occurring contaminants). Although scientific consensus on how best to address PFAS coexposures remains elusive, this was considered in the study quality evaluations and as part of the overall weight-of-evidence determination. To be a confounder, the co-occurring PFAS would need to be associated with both the PFAS of interest and the outcome, but not an intermediate in the causal pathway; such PFAS would be considered positive confounders if their effect estimate with the endpoint of interest is in the same direction as the primary PFAS of interest. If positive confounders are not accounted for, the anticipation is that any resultant bias would be away from the null.

A source of uncertainty in the epidemiological database was the potential for confounding by other PFAS (and other co-occurring contaminants) that co-occur and are actual confounders (i.e., associated with both the PFAS of interest and the outcome, but not an intermediate in the causal pathway between the two). In this example, such PFAS are considered positive confounders if their effect estimate with the endpoint of interest is in the same direction as the primary PFAS of interest. If positive confounders are not accounted for in the epidemiological study design or analysis phase, the anticipation is that any resultant bias would be away from the null. Certain statistical approaches can help address the challenges of evaluating the effects of numerous (often correlated) PFAS that may be present in the environment and estimated via different biomarkers and other measures. (i.e., those that adjust for at least one co-occurring exposure) can provide an estimate of the independent association for specific pollutants with the endpoint of interest. However, these models may not perform well when co-occurring exposures are highly correlated. Such correlation can lead to collinearity concerns and instability of modeling results. When exposures are highly correlated and additionally subject to different potential confounding factors (which may occur, e.g., when PFAS arise from different sources), coexposure amplification bias may be a concern (Weisskopf et al., 2018). Under this scenario, estimated associations from multi-PFAS adjusted models would be subject to greater bias compared with results from single-PFAS models.

Other mixture approaches are employed in epidemiological studies to characterize overall mixture effects and in some cases to “screen” large groups of exposures to identify exposure patterns and/or contributions, which may help determine which exposure(s) are most important to retain in further analyses. These statistical methods using dimension-reduction (e.g., principal component analysis, penalized modeling based on elastic net regression) and mixture methods (e.g., Bayesian kernel machine regression) are increasingly being used for identifying patterns among large groups of chemical exposures and help prioritize specific components/chemicals that contribute the highest proportion to the mixture. However, as noted by Meng et al. (2018), these approaches might be better suited as “prediction models to screen for a wide range of chemicals from different sources, and the interpretation of results might become less straightforward due to the necessary standardization of exposure values.” These regression model outputs also do not provide confidence intervals, which precludes evaluations of precision. Given these interpretation difficulties and the potential for coexposure amplification bias, which statistical approach best represents independent effects of specific pollutants within complex PFAS mixtures is unclear. An evaluation of single-pollutant (i.e., PFDA alone) models and other approaches is detailed below.

The objective herein is to assess whether there is any direct evidence for confounding in the studies by comparing results from multipollutant (mutually adjusted for other PFAS) models and results from single-pollutant (i.e., PFDA alone with other confounders adjusted for) models. Additional objectives were to compare relationships between co-occurring PFAS and to evaluate the extent to which these PFAS may be associated with a primary endpoint of interest (e.g., birth weight-related measures).

## F.3 PFDA AND PFAS COEXPOSURE STUDY RESULTS

In general, the stronger an association between coexposures, and the larger the effect sizes seen for the coexposure of interest, the more concern there would be for potential confounding. Table F-1 shows correlations between PFAS coexposures and PFDA reported from five studies with mutually adjusted PFAS data, including four medium confidence (Meng et al., 2018; Woods et al., 2017; Lenters et al., 2016; Robledo et al., 2015), one high Luo et al. (2021), and one low confidence study (Starling et al., 2017). As shown in the PFAS Systematic Review Protocol (see Appendix A) and in Table F-1, PFNA and PFDA often co-occur (as expected given some similar anticipated sources) across studies with a consistent correlation of 0.6 or higher. These results also show that other PFAS may not consistently co-occur with PFDA, as the magnitude of these relationships can vary significantly across studies.

Table F-1 PFAS correlation coefficients in mutually adjusted studies

Reference | Study setting | Confidence | Correlations with PFDA
Reference | Study setting | Confidence | PFOS | PFOA | PFNA | PFHxS
Luo et al. (2021) | Guangzhou, China | High | 0.68 | 0.13 | 0.85 | −0.03
Woods et al. (2017) | Cincinnati, Ohio, USA | Medium | 0.3 | 0.1 | 0.6 | 0.1
Lenters et al. (2016) | Greenland; Kharkiv, Ukraine; Warsaw, Poland | Medium | 0.78 | 0.50 | 0.60 | 0.35
Meng et al. (2018) | Denmark | Medium | 0.48 | 0.28 | 0.73 | 0.17
Robledo et al. (2015) | Michigan and Texas, USA | Medium | N/A | N/A | N/A | N/A
Starling et al. (2017) | Colorado, USA | Low | 0.49 | 0.56 | 0.65 | 0.27

The results for the six studies based on continuous PFDA data (expressed as change in mean birth weight per unit change in exposure) are compared and summarized below in Table F-2. Three of the studies included multiple PFAS as predictors in ordinary least squares regression models (Meng et al., 2018; Woods et al., 2017; Robledo et al., 2015). Luo et al. (2021) examined multipollutant associations on the basis of nonparametric Bayesian kernel machine regression modeling. Two studies (Starling et al., 2017; Lenters et al., 2016) examined multiple PFAS using elastic net regression models. Elastic net regression is a modeling approach to select independent predictors (from an initial group of potentially correlated predictors) for inclusion in the model using penalized shrinkage methods (Lenters et al., 2016). As shown in Table F-2, two of the six studies (Luo et al., 2021; Lenters et al., 2016) reported inverse associations for birth weight and PFDA from single-pollutant models. However, PFDA was not associated with birth weight changes in multipollutant models for either study. For example, Lenters et al. (2016) reported null results for PFDA in both their single-pollutant model and elastic net regression model, with only PFOA retained in the latter model. Starling et al. (2017) did not report birth weight deficits associated with PFDA on the basis of either single-pollutant or multipollutant models nor was PFDA selected for inclusion using elastic net regression. Meng et al. (2018) reported largely null results for PFDA in single-pollutant models but detected increases in mean birth weight with adjustment for PFOS, PFOA, PFNA, perfluoroheptane sulfonic acid (PFHpS), and PFHxS. Luo et al. (2021) reported large birth weight deficits (β = −97 g; 95% CI: −178, −16 per ln-unit PFDA increase) in single-pollutant PFDA model, but results were null in the multipollutant model. Lastly, Robledo et al. (2015) did not report results from single-pollutant models (or correlations) but in multipollutant models, they detected birth weight deficits associated with PFDA in female neonates only.

Given the moderate and strong correlations between PFDA and other PFAS, the magnitude of any associations that exist between these co-occurring PFAS and birth weight-related measures (and other developmental effects) may inform the potential for confounding of PFDA associations. For example, Lenters et al. (2016) reported birth weight deficits associated with increased levels of PFNA (β = −44.7 g; 95% CI: −92.0, 2.7 per 2SD ln-unit increase), PFOS (β = −68.8 g; 95% CI: −152.9, 15.2) and PFOA (β = −78.5 g; 95% CI: −137.0, −20.0) in single-pollutant models although only PFOA (β = −63.8 g; 95% CI: −122.8, −4.7) was retained in the elastic net regression model. Although birth weight deficits were not seen for PFDA in any of the regression models used by Starling et al. (2017), there were large mean birth weight deficits associated with increased exposure evaluated in single-pollutant models for both PFNA (β = −58 g; 95% CI: −104, −11 per ln-unit PFDA increase) and PFOA (β = −51 g; 95% CI: −97, −6). These deficits were larger in multipollutant models for both PFNA (β = −92 g; 95% CI: −167, −18) and PFOA (β = −70 g; 95% CI: −148, −9) but were attenuated when included in a penalized elastic net regression model (β = −33 g and −14 g, respectively). In the Woods et al. (2017) study, none of the five PFAS examined contributed greatly to the overall changes in mean birth weight when other environmental contaminants were considered in their elastic net model. Although Luo et al. (2021) reported birth weight deficits in single-pollutant models for several PFAS including PFDA and PFNA, only PFOS showed a large reduction based on Bayesian kernel machine regression results (β = −105.0 g; 95% CI: −209.4, −0.6 for Q4). Meng et al. (2018) reported similar deficits in birth weight associated with increased exposure to PFNA (β = −54.2 g; 95% CI: −105.8, −2.7 per log_2_unit PFDA increase) and PFOS (β= −55.5 g; 95% CI: −145.6, 34.5) in their model containing mutually adjusted PFAS; however, effects were seen in the opposite direction (increase in mean birth weight) for PFDA (β = 48.0 g; 95% CI: −0.6, 96.5) and PFOA (β = 49.5 g; 95% CI: −8.7, 107.9) in the same model. Finally, Robledo et al. (2015) reported that only PFOA was associated with large deficits in mean birth weight (β = −61.6 g; 95% CI: −159.2, 35.9 per SD ln-unit increase) among girls in multipollutant models, while among boys deficits were only seen for perfluorooctane sulfonamide (PFOSA) (β = −104.2 g; 95% CI: −194.2, −14.3) and PFDA (β = −53.4 g; 95% CI: −161.0, 54.2).

In the six studies using mutually adjusted PFAS approaches to address coexposures, there was no consistent evidence for birth weight deficits associated with increased exposure to PFDA. Among the five studies that examined both single and multipollutant models, none of the studies that showed birth weight deficits in single-pollutant models reported greater or more precise associations following statistical adjustment for other PFAS. Of the three studies showing some adverse effects (Luo et al., 2021; Lenters et al., 2016; Robledo et al., 2015), only one (Robledo et al., 2015) showed deficits in multipollutant models and this was limited to females only. Among the three studies that provided correlations among co-occurring PFAS and showed some evidence of adverse effects for any PFAS, the largest birth weight deficits were seen for PFNA (Meng et al., 2018; Starling et al., 2017), PFOA (Robledo et al., 2015), and PFOS (Luo et al., 2021). The correlation coefficients for PFDA and these three coexposures across these studies were all at least 0.50.

As noted in Section 3.2.3 of the Toxicological Review, 11 of 22 studies showed evidence of some associations with PFDA and mean birth weight in the overall population. Among these 11 studies, which included the 3 highlighted above, 7 (Yao et al., 2021; Kashino et al., 2020; Wikström et al., 2020; Li et al., 2017b; Swedish Environmental Protection Agency, 2017; Valvi et al., 2017; Lenters et al., 2016) showed deficits comparable in magnitude for PFNA and PFDA. Two studies showed larger deficits for PFDA compared with PFNA (Kwon et al., 2016; Robledo et al., 2015), and two studies showed larger deficits for PFNA compared with PFDA (Luo et al., 2021; Workman et al., 2019). Given these comparable results seen in most of these studies for both PFNA and PFDA and the moderately high correlations consistently reported between PFDA and PFNA, there is considerable uncertainty due to potential confounding by co-occurring PFAS in the existing literature. It remains unclear, however, if the consistency of birth weight deficits demonstrated from (categorical and continuous) results in the full set of 22 mean birth weight PFDA studies could be fully attributed to confounding by PFAS coexposures.

Table F-2 Impact of coexposure adjustment on estimated change in mean birth weight per unit change (ng/mL) in PFDA levels^a^

Reference | Study confidence | Single-PFAS model results (in grams) with 95% CIs^a^ | Multi-PFAS results (in grams) with 95% CIs^a^ | Elastic net regression results | Exposure comparison^b^ | Effect of adjustment on PFDA birth weight results | PFAS adjustments
Starling et al. (2017) | High | 11.5 (−37.3, 60.4) | 97.5 (31.5, 163.6) | 15.7 | ln-unit (ng/mL) increase | Slightly Strengthened | PFOS, PFOA, PFNA, PFHxS
Lenters et al. (2016) | Medium | −43.9 (−104.8, 17.0) | N/A | N/S | 2 SD ln-unit (ng/mL) increase | Attenuated | PFOS, PFOA, PFNA, PFUnDA, PFDoDA, PFHxS
Luo et al. (2021) | High | −96.8 (−178.0, −15.5) | 6.6 (−84.2, 97.3)^b^ | N/A | ln-unit (ng/mL) increase | Attenuated | PFOA, PFOS, PFBA, PFBS, PFHxS, PFNA, PFUnDA, PFDoDA, PFTrDA, 6:2 Cl-PFESA, 8:2 Cl-PFESA
Meng et al. (2018) | Medium | −9.0 (−43.2, 35.2) | 48.0 (−0.6, 96.5) | N/A | log_2_-unit (ng/mL) increase | Changed from Null to Positive | PFOS, PFOA, PFNA, PFHxS, PFHpS
Robledo et al. (2015) | Medium | N/A | −53.4 (−161.0, 54.2) Girls −1.8 (−90.6, 87.1) Boys^c^ | N/A | 1 SD ln-unit (ng/mL) increase | N/A | PFOA, PFOS, PFNA, PFOSA, Et-PFOSA-AcOH, Me-PFOSA-AcOH
Woods et al. (2017) | Medium | −12.6 (−56.8, 40.4)^d^ | N/A | N/S | log_10_-unit (ng/mL) increase | Attenuated | PFOS, PFOA, PFNA, PFUnDA, PFDoDA, PFHxS

N/A: not available; N/S: PFAS not selected in elastic net regression model.

a Models were based on ordinary least squares regression.

b Beta and 95% CIs estimated from Figure 3 of (Luo et al., 2021).

c The birth weight results tabulated here are all for the overall population (i.e., male, and female neonates combined), except for Robledo, which only reported sex-specific findings.

d The posterior 95% credible intervals reported for Woods et al. (2017) are based on a Bayesian hierarchical linear model.