# APPENDIX E ANALYSIS OF RELEVANT HIGH-THROUGHPUT SCREENING ASSAYS FROM EPA’S CHEMICALS DASHBOARD

## E.1 IN VITRO BIOACTIVITY DATA RELEVANT TO THE MECHANISMS OF PFDA-INDUCED LIVER EFFECTS

In vitro high-throughput screening (HTS) assays for perfluorodecanoic acid (PFDA) were downloaded from EPA's CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) ((U.S. EPA, 2022a), accessed November 3, 2022), which provides bioactivity data from the ToxCast and Tox21 collaborative projects. Available information most pertinent to the analysis of the potential mechanisms of PFDA-induced liver effects was extracted to supplement and augment mechanistic findings from studies in the peer-reviewed literature previously described. Results (active/inactive, AC50 values, and scaled activity) from in vitro assays in human hepatoma HepG2 cells and metabolically competent human hepatic progenitor cells (HepaRG) cells were compiled. Background control assays were filtered out along with nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control ("_dn"). Bioactivity data were analyzed on the basis of the type of biological response or gene target using the annotation structure within the ToxCast assay summary information ((U.S. EPA, 2022a), accessed November 3, 2022).

PFDA was active in 74 of 238 unique assay endpoints (∼31%) in HepG2 and HepaRG cells, inducing a range of cell- and gene-specific changes (see Figure E-1 and Table E-1). PFDA was associated with cell cycle arrest and proliferation responses and induction of markers of oxidative stress and cell death (see Table E-1). Alterations in nuclear size and mitochondrial mass were also observed in HTS assays for PFDA with no apparent changes in microtubule conformation and mitochondrial membrane potential and respiration (see Table E-1). Further, PFDA caused upregulation of transcriptional activity that occurred generally at lower effective concentrations (i.e., AC50) compared with the cell-based responses (see Figure E-1). Specifically, PFDA induced the expression of CYP450 enzymes, growth factors, transporters, and transcriptional factors, including several xenobiotic-sensing nuclear receptors previously implicated in the mechanisms of liver toxicity of PFDA or other PFAS (i.e., PPARα/γ, PXR, and FXR) (see Figure E-2 and Table E-1).

In summary, PFDA elicited in vitro responses in HTS assays conducted in HepG2 and HepaRG cells most consistently for cellular stress and cytotoxicity. Additionally, induction of gene target pathways corresponding to several transcriptional factor/nuclear receptor activities occurred upstream of the cell-mediated responses, albeit at similar effective concentrations.

Nuclear receptor activities were investigated more closely to provide further insights into the putative interaction of PFDA with these receptor-mediated signaling pathways in ToxCast/Tox21 assays profiling multiple endpoints (e.g., receptor binding, coregulator recruitment, and gene transactivation) and cell types (see Table E-2). As mentioned above, PFDA induced activity of specific steroid/xenobiotic-sensing receptors, most notably FXR, PPAR, and PXR (see Figure E-3A). PFDA interacted with the human FXR in a receptor-ligand binding assay evaluating agonist activity and in one of two independent assays measuring transcriptional activity in HepG2 cells but was inactive in four FXR-related assays in human embryonic kidney cells (HEK293T), targeting receptor/cofactor recruitment and agonist/antagonist activities (see Table E-2). Upregulation of transcriptional activity for PPARα and PPARγ but not PPARβ/δ (PPARD) was demonstrated in HepG2 cells, and PFDA was found to interact with the human PPARγ (but not human PPARα) in a receptor-ligand binding assay (see Table E-2). No activity was detected in assays conducted in HEK293T cells profiling agonist/antagonist activities for PPARγ or PPARβ/δ or receptor/cofactor recruitment for PPARγ (see Table E-2). PFDA was active in two of four assays for PXR, showing transcriptional induction in HepG2 cells (one of two independent assays) and direct binding to the human PXR but no activity in an agonist assay using HepG2 cells (see Table E-2). HNF4A, NURR1, RAR, ROR, RXR, and VDR were also targets of PFDA in reporter gene assays using HepG2 cells, and antagonist activity toward ERR was reported in HEK293T cells (see Table E-2). PFDA targeted the ER and AR in in vitro HTS assays; however, overall activity for these receptors was low (see Appendix E.2 for additional details on the HTS results for the ER and AR). PFDA showed no appreciable activity in assays for GR, CAR, LXR, TR, and PR (see Figure E-3A). Comparison of AC50 values across the nuclear receptor assays indicate that PFDA exerts the highest potency toward the human FXR with the lowest AC50 of 0.52 μM in a cell-free receptor binding assay (see Figure E-3B), which is below the lower bound of the ToxCast cytotoxicity limit estimated for this chemical (7.108 μM) ((U.S. EPA, 2022a), accessed November 3, 2022).

Altogether, the results of the ToxCast/Tox21 HTS analysis provide some mechanistic support for the PFDA-induced liver effects. PFDA caused upregulation of transcriptional activity in human hepatoma HepG2 cells involving multiple nuclear receptor pathways previously implicated in the MOA for PFDA-induced liver toxicity, namely PXR, FXR, and PPARα/γ. These target gene responses were associated with the induction of cellular stress/cytotoxicity. PFDA also interacted directly with the human PXR, FXR, and PPARγ in receptor binding assays, demonstrating particular sensitivity for the human FXR at concentrations below those associated with cytotoxicity and suggesting that FXR may be an important target for this chemical.

Figure E-1 Bioactivity data for PFDA from in vitro HTS ToxCast/Tox21 assays conducted in human liver cell lines (HepG2 and HepaRG cells).

Scatterplots show AC50 and scaled activity values from assays visualized according to the type of biological response. AC50 values refer to the concentration that elicits half maximal response and the scaled activity refers to the response value divided by the activity cutoff. Assays for which chemicals were inactive are not displayed. Additional information on all tested assays in HepG2 and HepaRG cells can be found in Table E-1.

Figure E-1. Bioactivity data for PFDA from in vitro HTS ToxCast/Tox21 assays conducted in human liver cell lines (HepG2 and HepaRG cells).

Figure E-2 Analysis of PFDA-induced upregulation of transcriptional activity in ToxCast/Tox21 assays conducted in human liver cell lines (HepG2 and HepaRG cells).

Bar graph compares AC50 values (concentration at half maximal response) for active assays. The scale for the AC50 values is shown in reverse order to visualize the most sensitive assays (the higher bar indicates a lower AC50 value). Additional information on the transcriptional activity assays can be found in Table E-1.

Figure E-2. Analysis of PFDA-induced upregulation of transcriptional activity in ToxCast/Tox21 assays conducted in human liver cell lines (HepG2 and HepaRG cells).

Figure E-3 Analysis of PFDA-induced nuclear receptor-related activities in ToxCast/Tox21 assays across multiple endpoints and cell types.

Panel A summarizes active/inactive calls from nuclear receptor assays mapped to specific target genes. Panel B compares AC50 values (concentration at half maximal response) for active assays. The scale for the AC50 values is shown in reverse order to visualize the most sensitive nuclear receptor activities (the higher bar indicates a lower AC50 value). Additional information on all tested nuclear receptor-related assays can be found in Table E-2.

AR = androgen receptor; CAR = constitutive androgen receptor; ER = estrogen receptor; ERR = estrogen-related receptor; FXR = farnesoid X receptor; GR = glucocorticoid receptor; HNF4A = hepatocyte nuclear factors 4 alpha; LXR = liver X receptor; NURR1 = nuclear receptor related-1 protein; PPAR = peroxisome proliferator-activated receptor; PXR = pregnane X receptor; RAR = retinoid acid receptor; ROR = RAR-related orphan receptor; RXR = retinoid X receptor; TR = thyroid hormone receptor; VDR = vitamin D receptor.

Figure E-3. Analysis of PFDA-induced nuclear receptor-related activities in ToxCast/Tox21 assays across multiple endpoints and cell types.

Table E-1 Bioactivity summary for PFDA from in vitro HTS assays from ToxCast/Tox21 conducted in human liver cell lines (HepG2 and HepaRG cells) and grouped by biological response/target^a, b^

Assay name | Activity call | Scaled activity | AC50 (μM) | Assay design | Cell line
Cell cycle
APR_HepG2_CellCycleArrest_72h_dn | Active | 1.23 | 69.51 | Morphology reporter | HepG2
APR_HepG2_MitoticArrest_24h_up | Active | 2.25 | 107.91 | Morphology reporter | HepG2
APR_HepG2_MitoticArrest_72h_up | Active | 2.44 | 98.57 | Morphology reporter | HepG2
APR_HepG2_CellCycleArrest_24h_dn | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_CellCycleArrest_24h_up | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_CellCycleArrest_72h_up | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_MitoticArrest_24h_dn | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_MitoticArrest_72h_dn | Inactive | NA | NA | Morphology reporter | HepG2
Cellular/organelle conformation
APR_HepG2_NuclearSize_24h_dn | Active | 1.33 | 128.23 | Morphology reporter | HepG2
APR_HepG2_NuclearSize_72h_dn | Active | 1.51 | 121.20 | Morphology reporter | HepG2
APR_HepG2_MicrotubuleCSK_24h_dn | Inactive | NA | NA | Conformation reporter | HepG2
APR_HepG2_MicrotubuleCSK_24h_up | Inactive | NA | NA | Conformation reporter | HepG2
APR_HepG2_MicrotubuleCSK_72h_dn | Inactive | NA | NA | Conformation reporter | HepG2
APR_HepG2_MicrotubuleCSK_72h_up | Inactive | NA | NA | Conformation reporter | HepG2
APR_HepG2_NuclearSize_24h_up | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_NuclearSize_72h_up | Inactive | NA | NA | Morphology reporter | HepG2
Cellular stress/cytotoxicity
APR_HepG2_CellLoss_24h_dn | Active | 3.75 | 108.88 | Viability reporter | HepG2
APR_HepG2_CellLoss_72h_dn | Active | 3.63 | 106.54 | Viability reporter | HepG2
APR_HepG2_p53Act_24h_up | Active | 1.61 | 107.89 | Viability reporter | HepG2
APR_HepG2_p53Act_72h_up | Active | 2.28 | 113.49 | Viability reporter | HepG2
APR_HepG2_P-H2AX_24h_up | Active | 2.35 | 112.97 | Viability reporter | HepG2
APR_HepG2_P-H2AX_72h_up | Active | 2.88 | 108.81 | Viability reporter | HepG2
APR_HepG2_StressKinase_72h_up | Active | 1.50 | 122.76 | Enzyme reporter | HepG2
LTEA_HepaRG_LDH_cytotoxicity | Active | 7.31 | 66.39 | Viability reporter | HepaRG
APR_HepG2_CellLoss_24h_up | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_CellLoss_72h_up | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_p53Act_24h_dn | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_p53Act_72h_dn | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_P-H2AX_24h_dn | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_P-H2AX_72h_dn | Inactive | NA | NA | Viability reporter | HepG2
APR_HepG2_StressKinase_24h_dn | Inactive | NA | NA | Enzyme reporter | HepG2
APR_HepG2_StressKinase_24h_up | Inactive | NA | NA | Enzyme reporter | HepG2
APR_HepG2_StressKinase_72h_dn | Inactive | NA | NA | Enzyme reporter | HepG2
ATG_XTT_Cytotoxicity_up | Inactive | NA | NA | Viability reporter | HepG2
CCTE_Simmons_MITO_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_AhR_LUC_Agonist_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_ARE_BLA_agonist_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_CAR_Agonist_viabillity | Inactive | NA | NA | Viability reporter | HepG2
TOX21_CAR_Antagonist_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_CASP3_HEPG2 | Inactive | NA | NA | Inducible reporter | HepG2
TOX21_CASP3_HEPG2_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_MMP_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_PXR_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_00hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_08hr_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_16hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_24hr_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_32hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_FLO_40hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_00hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_08hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_16hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_24hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_32hr_ctrl_viability | Inactive | NA | NA | Viability reporter | HepG2
TOX21_RT_HEPG2_GLO_40hr_viability | Inactive | NA | NA | Viability reporter | HepG2
Mitochondrial toxicity
APR_HepG2_MitoMass_24h_dn | Active | 4.72 | 117.36 | Morphology reporter | HepG2
APR_HepG2_MitoMass_72h_dn | Active | 4.83 | 113.92 | Morphology reporter | HepG2
APR_HepG2_MitoMass_24h_up | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_MitoMass_72h_up | Inactive | NA | NA | Morphology reporter | HepG2
APR_HepG2_MitoMembPot_24h_dn | Inactive | NA | NA | Membrane potential reporter | HepG2
APR_HepG2_MitoMembPot_24h_up | Inactive | NA | NA | Membrane potential reporter | HepG2
APR_HepG2_MitoMembPot_72h_dn | Inactive | NA | NA | Membrane potential reporter | HepG2
APR_HepG2_MitoMembPot_72h_up | Inactive | NA | NA | Membrane potential reporter | HepG2
CCTE_Simmons_MITO_basal_resp_rate_OC R_dn | Inactive | NA | NA | Respirometric reporter | HepG2
CCTE_Simmons_MITO_basal_resp_rate_OC R_up | Inactive | NA | NA | Respirometric reporter | HepG2
CCTE_Simmons_MITO_inhib_resp_rate_OC R_dn | Inactive | NA | NA | Respirometric reporter | HepG2
CCTE_Simmons_MITO_inhib_resp_rate_OC R_up | Inactive | NA | NA | Respirometric reporter | HepG2
CCTE_Simmons_MITO_max_resp_rate_OCR_dn | Inactive | NA | NA | Respirometric reporter | HepG2
CCTE_Simmons_MITO_max_resp_rate_OCR_up | Inactive | NA | NA | Respirometric reporter | HepG2
TOX21_MMP_ratio_down | Inactive | NA | NA | Membrane potential reporter | HepG2
TOX21_MMP_ratio_up | Inactive | NA | NA | Membrane potential reporter | HepG2
Upregulation of transcriptional activity
ATG_EGR_CIS_up | Active | 1.19 | 19.92377 | Inducible reporter | HepG2
ATG_ERa_TRANS_up | Active | 1.50 | 16.43561 | Inducible reporter | HepG2
ATG_FXR_TRANS_up | Active | 2.28 | 18.99931 | Inducible reporter | HepG2
ATG_HNF4a_TRANS_up | Active | 1.59 | 80.32058 | Inducible reporter | HepG2
ATG_HSE_CIS_up | Active | 2.31 | 28.98294 | Inducible reporter | HepG2
ATG_MRE_CIS_up | Active | 1.78 | 12.43083 | Inducible reporter | HepG2
ATG_NRF2_ARE_CIS_up | Active | 3.54 | 20.6361 | Inducible reporter | HepG2
ATG_NURR1_TRANS_up | Active | 1.87 | 25.56622 | Inducible reporter | HepG2
ATG_Pax6_CIS_up | Active | 1.56 | 29.70391 | Inducible reporter | HepG2
ATG_PPARα_TRANS_up | Active | 1.30 | 18.12921 | Inducible reporter | HepG2
ATG_PPARg_TRANS_up | Active | 1.31 | 11.97573 | Inducible reporter | HepG2
ATG_PPRE_CIS_up | Active | 2.29 | 25.89358 | Inducible reporter | HepG2
ATG_PXR_TRANS_up | Active | 1.42 | 30.14653 | Inducible reporter | HepG2
ATG_RARg_TRANS_up | Active | 1.50 | 21.20087 | Inducible reporter | HepG2
ATG_RORE_CIS_up | Active | 1.41 | 21.068 | Inducible reporter | HepG2
ATG_RXRb_TRANS_up | Active | 4.26 | 16.95397 | Inducible reporter | HepG2
ATG_TGFb_CIS_up | Active | 2.94 | 14.44227 | Inducible reporter | HepG2
ATG_VDRE_CIS_up | Active | 1.25 | 19.38327 | Inducible reporter | HepG2
ATG_Xbp1_CIS_up | Active | 2.05 | 31.73703 | Inducible reporter | HepG2
LTEA_HepaRG_ABCC3_up | Active | 1.71 | 17.53302 | Inducible reporter | HepaRG
LTEA_HepaRG_ABCG2_up | Active | 1.08 | 11.2217 | Inducible reporter | HepaRG
LTEA_HepaRG_BAX_up | Active | 3.20 | 22.88926 | Inducible reporter | HepaRG
LTEA_HepaRG_BCL2_up | Active | 6.13 | 14.76859 | Inducible reporter | HepaRG
LTEA_HepaRG_BCL2L11_up | Active | 3.41 | 22.55949 | Inducible reporter | HepaRG
LTEA_HepaRG_CASP8_up | Active | 2.45 | 33.09058 | Inducible reporter | HepaRG
LTEA_HepaRG_CCND1_up | Active | 3.50 | 21.35921 | Inducible reporter | HepaRG
LTEA_HepaRG_CDKN1A_up | Active | 2.49 | 13.57402 | Inducible reporter | HepaRG
LTEA_HepaRG_CFLAR_up | Active | 3.93 | 23.40259 | Inducible reporter | HepaRG
LTEA_HepaRG_CYP1A1_up | Active | 1.40 | 37.12706 | Inducible reporter | HepaRG
LTEA_HepaRG_CYP2C19_up | Active | 1.08 | 0.911362 | Inducible reporter | HepaRG
LTEA_HepaRG_CYP4A11_up | Active | 3.00 | 4.084149 | Inducible reporter | HepaRG
LTEA_HepaRG_CYP4A22_up | Active | 2.39 | 5.093503 | Inducible reporter | HepaRG
LTEA_HepaRG_DDIT3_up | Active | 9.91 | 24.56621 | Inducible reporter | HepaRG
LTEA_HepaRG_EGR1_up | Active | 2.35 | 27.13929 | Inducible reporter | HepaRG
LTEA_HepaRG_EZR_up | Active | 2.29 | 20.2641 | Inducible reporter | HepaRG
LTEA_HepaRG_FAS_up | Active | 2.46 | 23.51647 | Inducible reporter | HepaRG
LTEA_HepaRG_FOXO3_up | Active | 1.08 | 17.79771 | Inducible reporter | HepaRG
LTEA_HepaRG_GADD45B_up | Active | 1.37 | 316.2278 | Inducible reporter | HepaRG
LTEA_HepaRG_GADD45G_up | Active | 3.77 | 16.26879 | Inducible reporter | HepaRG
LTEA_HepaRG_GCLC_up | Active | 2.58 | 13.26529 | Inducible reporter | HepaRG
LTEA_HepaRG_HSPA1A_up | Active | 2.48 | 86.07431 | Inducible reporter | HepaRG
LTEA_HepaRG_ICAM1_up | Active | 1.37 | 16.93707 | Inducible reporter | HepaRG
LTEA_HepaRG_IGFBP1_up | Active | 5.77 | 24.20317 | Inducible reporter | HepaRG
LTEA_HepaRG_IL6_up | Active | 4.33 | 39.10404 | Inducible reporter | HepaRG
LTEA_HepaRG_JUN_up | Active | 1.15 | 13.67962 | Inducible reporter | HepaRG
LTEA_HepaRG_KCNK1_up | Active | 1.37 | 31.6189 | Inducible reporter | HepaRG
LTEA_HepaRG_KRT19_up | Active | 1.75 | 13.95732 | Inducible reporter | HepaRG
LTEA_HepaRG_LPL_up | Active | 3.94 | 20.11038 | Inducible reporter | HepaRG
LTEA_HepaRG_MMP1_up | Active | 3.30 | 38.55908 | Inducible reporter | HepaRG
LTEA_HepaRG_MMP10_up | Active | 3.14 | 35.00735 | Inducible reporter | HepaRG
LTEA_HepaRG_MYC_up | Active | 3.67 | 17.50487 | Inducible reporter | HepaRG
LTEA_HepaRG_NFE2L2_up | Active | 1.16 | 18.16403 | Inducible reporter | HepaRG
LTEA_HepaRG_PDK4_up | Active | 4.93 | 24.64551 | Inducible reporter | HepaRG
LTEA_HepaRG_PEG10_up | Active | 2.01 | 12.83903 | Inducible reporter | HepaRG
LTEA_HepaRG_PPP2R4_up | Active | 3.31 | 23.18532 | Inducible reporter | HepaRG
LTEA_HepaRG_TGFA_up | Active | 3.96 | 21.42175 | Inducible reporter | HepaRG
LTEA_HepaRG_TGFB1_up | Active | 1.48 | 18.53422 | Inducible reporter | HepaRG
LTEA_HepaRG_TP53_up | Active | 5.61 | 13.70365 | Inducible reporter | HepaRG
TOX21_ARE_BLA_agonist_ratio | Active | 4.79 | 39.41989 | Inducible reporter | HepG2
ATG_Ahr_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_AP_1_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_AP_2_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_AR_TRANS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_BRE_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_C_EBP_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_CAR_TRANS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_CRE_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_DR4_LXR_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_DR5_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_E_Box_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_E2F_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_ERE_CIS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_ERRa_TRANS_up | Inactive | 1 | 1 | Inducible reporter | HepG2
ATG_ERRg_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Ets_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_FoxA2_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_FoxO_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_GATA_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_GLI_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_GR_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_GRE_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_HIF1a_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_HNF6_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_IR1_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_ISRE_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_LXRa_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_LXRb_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Myb_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Myc_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_NF_kB_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_NFI_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_NRF1_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Oct_MLP_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_p53_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_PBREM_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_PPARd_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_PXRE_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_RARa_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_RARb_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_RORb_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_RORg_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_RXRa_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Sox_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_Sp1_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_SREBP_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_STAT3_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_TCF_b_cat_CIS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_THRa1_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
ATG_VDR_TRANS_up | Inactive | NA | NA | Inducible reporter | HepG2
LTEA_HepaRG_ABCB1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ABCB11_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ABCC2_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ACLY_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ACOX1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ADK_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_ALPP_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_APOA5_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_BAD_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_BID_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CASP3_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CAT_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP1A2_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP24A1_1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP2B6_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP2C8_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP2C9_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP2E1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP3A4_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP3A5_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP3A7_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_CYP7A1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_EGF_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_FABP1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_FASN_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_FMO3_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_FOXO1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_GADD45A_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_GSTA2_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_GSTM3_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_HGF_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_HIF1A_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_HMGCS2_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_IGF1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_IL6R_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_LIPC_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_MIR122_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_MMP3_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_NFKB1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_NQO1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_PTEN_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SDHB_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SLC10A1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SLC22A1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SLC22A6_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SLCO1B1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_STAT3_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_SULT2A1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_THRSP_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_TIMP1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_TNFRSF1A_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_UGT1A1_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_UGT1A6_up | Inactive | NA | NA | Inducible reporter | HepaRG
LTEA_HepaRG_XBP1_up | Inactive | NA | NA | Inducible reporter | HepaRG
TOX21_AhR_LUC_Agonist | Inactive | NA | NA | Inducible reporter | HepG2
TOX21_CAR_Agonist | Inactive | NA | NA | Inducible reporter | HepG2
TOX21_CAR_Antagonist | Inactive | NA | NA | Inducible reporter | HepG2
TOX21_PXR_Agonist | Inactive | NA | NA | Inducible reporter | HepG2

NA = not applicable.

a Data were sourced from EPA’s CompTox Chemicals Dashboard ((U.S. EPA, 2022a), accessed November 3, 2022).

b Background control assays and nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control (“_dn”) are not presented herein.

Table E-2 Bioactivity summary for PFDA from in vitro HTS assays evaluating nuclear receptor-related activities from ToxCast/Tox21 across multiple endpoints and cell types^a, b, c^

Assay name | Activity call | Scaled Activity | AC50 (μM) | Biological target | Assay design | Organism | Tissue | Cell line
ATG_CAR_TRANS_up | Inactive | NA | NA | CAR (NR1I3) | Inducible reporter | human | liver | HepG2
ATG_PBREM_CIS_up | Inactive | NA | NA | CAR (NR1I3) | Inducible reporter | human | liver | HepG2
TOX21_CAR_Agonist | Inactive | NA | NA | CAR (NR1I3) | Inducible reporter | human | liver | HepG2
TOX21_CAR_Antagonist | Inactive | NA | NA | CAR (NR1I3) | Inducible reporter | human | liver | HepG2
TOX21_ERR_Antagonist | Active | 1.31 | 6.62 | ERR (ESRRA) | Inducible reporter | human | kidney | HEK293T
ATG_ERRa_TRANS_up | Inactive | NA | NA | ERR (ESRRA) | Inducible reporter | human | liver | HepG2
ATG_ERRg_TRANS_up | Inactive | NA | NA | ERR (ESRRA) | Inducible reporter | human | liver | HepG2
TOX21_ERR_Agonist | Inactive | NA | NA | ERR (ESRRA) | Inducible reporter | human | kidney | HEK293T
TOX21_PGC_ERR_Agonist | Inactive | NA | NA | ERR (ESRRA) | Inducible reporter | human | kidney | HEK293T
TOX21_PGC_ERR_Antagonist | Inactive | NA | NA | ERR (ESRRG) | Inducible reporter | human | kidney | HEK293T
ATG_FXR_TRANS_up | Active | 2.28 | 19.00 | FXR (NR1H4) | Inducible reporter | human | liver | HepG2
NVS_NR_hFXR_Agonist | Active | 5.52 | 0.52 | FXR (NR1H4) | Binding reporter | human | NA | NA
ATG_IR1_CIS_up | Inactive | NA | NA | FXR (NR1H4) | Inducible reporter | human | liver | HepG2
OT_FXR_FXRSRC1_0480 | Inactive | NA | NA | FXR (NR1H4) | Binding reporter | human | kidney | HEK293T
OT_FXR_FXRSRC1_1440 | Inactive | NA | NA | FXR (NR1H4) | Binding reporter | human | kidney | HEK293T
TOX21_FXR_BLA_agonist_ratio | Inactive | NA | NA | FXR (NR1H4) | Inducible reporter | human | kidney | HEK293T
TOX21_FXR_BLA_antagonist_ratio | Inactive | NA | NA | FXR (NR1H4) | Inducible reporter | human | kidney | HEK293T
ATG_GR_TRANS_up | Inactive | NA | NA | GR (NR3C1) | Inducible reporter | human | liver | HepG2
ATG_GRE_CIS_up | Inactive | NA | NA | GR (NR3C1) | Inducible reporter | human | liver | HepG2
NVS_NR_hGR | Inactive | NA | NA | GR (NR3C1) | Binding reporter | human | NA | NA
TOX21_GR_BLA_Agonist_ratio | Inactive | NA | NA | GR (NR3C1) | Inducible reporter | human | cervix | HeLa
TOX21_GR_BLA_Antagonist_ratio | Inactive | NA | NA | GR (NR3C1) | Inducible reporter | human | cervix | HeLa
ATG_HNF4a_TRANS_up | Active | 1.59 | 80.32 | HNF4A | Inducible reporter | human | liver | HepG2
ATG_LXRb_TRANS_up | Inactive | NA | NA | LXR (NR1H2) | Inducible reporter | human | liver | HepG2
ATG_DR4_LXR_CIS_up | Inactive | NA | NA | LXR (NR1H2\|NR1H3) | Inducible reporter | human | liver | HepG2
ATG_LXRa_TRANS_up | Inactive | NA | NA | LXR (NR1H3) | Inducible reporter | human | liver | HepG2
ATG_NURR1_TRANS_up | Active | 1.87 | 25.57 | NURR1 (NR4A2) | Inducible reporter | human | liver | HepG2
ATG_PPARα_TRANS_up | Active | 1.30 | 18.13 | PPAR (PPARα) | Inducible reporter | human | liver | HepG2
NVS_NR_hPPARα | Inactive | NA | NA | PPAR (PPARα) | Binding reporter | human | NA | NA
ATG_PPARd_TRANS_up | Inactive | NA | NA | PPAR (PPARD) | Inducible reporter | human | liver | HepG2
TOX21_PPARd_BLA_agonist_ratio | Inactive | NA | NA | PPAR (PPARD) | Inducible reporter | human | kidney | HEK293T
TOX21_PPARd_BLA_antagonist_ratio | Inactive | NA | NA | PPAR (PPARD) | Inducible reporter | human | kidney | HEK293T
ATG_PPARg_TRANS_up | Active | 1.31 | 11.98 | PPAR (PPARG) | Inducible reporter | human | liver | HepG2
NVS_NR_hPPARg | Active | 5.15 | 13.73 | PPAR (PPARG) | Binding reporter | human | NA | NA
OT_PPARg_PPARgSRC1_0480 | Inactive | NA | NA | PPAR (PPARG) | Binding reporter | human | kidney | HEK293T
OT_PPARg_PPARgSRC1_1440 | Inactive | NA | NA | PPAR (PPARG) | Binding reporter | human | kidney | HEK293T
TOX21_PPARg_BLA_Agonist_ratio | Inactive | NA | NA | PPAR (PPARG) | Inducible reporter | human | kidney | HEK293T
TOX21_PPARg_BLA_antagonist_ratio | Inactive | NA | NA | PPAR (PPARG) | Inducible reporter | human | kidney | HEK293
ATG_PPRE_CIS_up | Active | 2.29 | 25.89 | PPAR (PPARα\|PPARD\|PPARG) | Inducible reporter | human | liver | HepG2
TOX21_PR_BLA_Agonist_ratio | Inactive | NA | NA | PR (PGR) | Inducible reporter | human | kidney | HEK293T
TOX21_PR_BLA_Antagonist_ratio | Inactive | NA | NA | PR (PGR) | Inducible reporter | human | kidney | HEK293T
ATG_PXR_TRANS_up | Active | 1.42 | 30.15 | PXR (NR1I2) | Inducible reporter | human | liver | HepG2
NVS_NR_hPXR | Active | 2.34 | 32.07 | PXR (NR1I2) | Binding reporter | human | NA | NA
ATG_PXRE_CIS_up | Inactive | NA | NA | PXR (NR1I2) | Inducible reporter | human | liver | HepG2
TOX21_PXR_Agonist | Inactive | NA | NA | PXR (NR1I2) | Inducible reporter | human | liver | HepG2
ATG_RARa_TRANS_up | Inactive | NA | NA | RAR (RARA) | Inducible reporter | human | liver | HepG2
TOX21_RAR_LUC_Agonist | Inactive | NA | NA | RAR (RARA) | Inducible reporter | mouse | embryo | C3H10T1/2
TOX21_RAR_LUC_Antagonist | Inactive | NA | NA | RAR (RARA) | Inducible reporter | mouse | embryo | C3H10T1/2
ATG_RARb_TRANS_up | Inactive | NA | NA | RAR (RARB) | Inducible reporter | human | liver | HepG2
ATG_RARg_TRANS_up | Active | 1.50 | 21.20 | RAR (RARG) | Inducible reporter | human | liver | HepG2
ATG_DR5_CIS_up | Inactive | NA | NA | RAR (RARA\|RARB\|RARG) | Inducible reporter | human | liver | HepG2
ATG_RORb_TRANS_up | Inactive | NA | NA | ROR (RORB) | Inducible reporter | human | liver | HepG2
ATG_RORg_TRANS_up | Inactive | NA | NA | ROR (RORC) | Inducible reporter | human | liver | HepG2
TOX21_RORg_LUC_CHO_Antagonist | Inactive | NA | NA | ROR (RORC) | Inducible reporter | Chinese hamster | ovary | CHO-K1
ATG_RORE_CIS_up | Active | 1.41 | 21.07 | ROR (RORA\|RORB\|RORC) | Inducible reporter | human | liver | HepG2
ATG_RXRa_TRANS_up | Inactive | NA | NA | RXR (RXRA) | Inducible reporter | human | liver | HepG2
OT_NURR1_NURR1RXRa_0480 | Inactive | NA | NA | RXR (RXRA) | Binding reporter | human | kidney | HEK293T
OT_NURR1_NURR1RXRa_1440 | Inactive | NA | NA | RXR (RXRA) | Binding reporter | human | kidney | HEK293T
ATG_RXRb_TRANS_up | Active | 4.26 | 16.95 | RXR (RXRB) | Inducible reporter | human | liver | HepG2
ATG_THRa1_TRANS_up | Inactive | NA | NA | TR (THRA) | Inducible reporter | human | liver | HepG2
TOX21_TR_LUC_GH3_Agonist | Inactive | NA | NA | TR (THRA\|THRB) | Inducible reporter | rat | pituitary gland | GH3
TOX21_TR_LUC_GH3_Antagonist | Inactive | NA | NA | TR (THRA\|THRB) | Inducible reporter | rat | pituitary gland | GH3
ATG_VDRE_CIS_up | Active | 1.25 | 19.38 | VDR | Inducible reporter | human | liver | HepG2
ATG_VDR_TRANS_up | Inactive | NA | NA | VDR | Inducible reporter | human | liver | HepG2
TOX21_VDR_BLA_agonist_ratio | Inactive | NA | NA | VDR | Inducible reporter | human | kidney | HEK293T
TOX21_VDR_BLA_antagonist_ratio | Inactive | NA | NA | VDR | Inducible reporter | human | kidney | HEK293T

NA = not applicable.

a Data were sourced from EPA’s CompTox Chemicals Dashboard ((U.S. EPA, 2022a), accessed November 3, 2022).

b Nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control (“_dn”) are not presented herein.

c In vitro bioactivity data for the AR and ER are summarized in detail in Appendix E.2 and, therefore, are not presented herein.

## E.2 IN VITRO BIOACTIVITY DATA RELEVANT TO THE POTENTIAL MECHANISMS OF REPRODUCTIVE TOXICITY

HTS screening ToxCast assays profiling in vitro activities for the AR, ER, and steroid hormone biosynthesis were sourced from EPA's CompTox Chemicals Dashboard ((U.S. EPA, 2019), accessed November 3, 2022) to investigate potential mechanisms of disruption of steroid hormone receptor activation and steroidogenesis that may be important for the reproductive toxicity of PFDA.

The suite of ToxCast assays and model predictions for the ER and AR encompass several endpoints in the signaling pathway of these receptors (e.g., receptor binding, receptor dimerization, cofactor recruitment, DNA binding, gene expression, and cell proliferation) across multiple in vitro models. PFDA was active in 2 of 17 AR assays (13%), demonstrating binding to the AR in rat prostrate tissue and AR-induced cell proliferation in a human prostate carcinoma cell line (22Rv1), but no activity in assays for cofactor recruitment and AR agonist/antagonist transactivation conducted primarily in human cell lines (see Table E-3). In ER assays, PFDA was active in 2 of 21 assays (11%), demonstrating activity for the ERα (ESR1) in 1 of 2 assays measuring RNA transcription in human hepatoma HepG2 cells and in an antagonist transactivation assay measuring protein expression in human embryonic kidney HEK293T cells (see Table E-3). PFDA was inactive in receptor binding assays for the ERα in human, bovine, and mouse tissues and in ER α/β assays for receptor dimerization, transcription factor-DNA binding, agonist transactivation, and ER-induced cell proliferation in different human cell lines. The AC50 values for the active ER and AR assays ranged from 8.40 to 62.3 μM, which are above the lower bound of the estimated ToxCast cytotoxicity limit (7.108 μM) ((U.S. EPA, 2022a), accessed November 3, 2022). ToxCast model predictions incorporating in vitro assay results and nonspecific responses such as cytotoxicity suggest that PFDA is inactive for both ER/AR agonist and antagonist pathways (AUC = 0) (see Table E-4).

The ToxCast database also included in vitro assays related to the regulation of steroidogenesis. PFDA showed a lack of activity in a single assay measuring inhibition of transcriptional activity for the aromatase gene (CYP19A1) in human breast cancer MCF-7 cells and several assays measuring biosynthesis of steroid hormones including glucocorticoids, androgens, estrogens, and progestogens in adrenal gland H295R cells (see Table E-5).

Table E-3 Bioactivity summary for PFDA from in vitro HTS assays evaluating activities for the AR, ER^a, b^

Assay name | Activity call | Scaled activity | AC50 (μM) | Biological target | Assay design | Organism | Tissue | Cell line
ACEA_AR_antagonist_80hr | Active | 9.34 | 62.3 | AR | Growth reporter | human | prostate | 22Rv1
NVS_NR_rAR | Active | 2.47 | 8.40 | AR | Binding reporter | rat | prostate | NA
ACEA_AR_agonist_80hr | Inactive | NA | NA | AR | Growth reporter | human | prostate | 22Rv1
ATG_AR_TRANS_up | Inactive | NA | NA | AR | Inducible reporter | human | liver | HepG2
OT_AR_ARELUC_AG_1440 | Inactive | NA | NA | AR | Inducible reporter | Chinese hamster | ovary | CHO-K1
OT_AR_ARSRC1_0480 | Inactive | NA | NA | AR | Binding reporter | human | kidney | HEK293T
OT_AR_ARSRC1_0960 | Inactive | NA | NA | AR | Binding reporter | human | kidney | HEK293T
TOX21_AR_BLA_Agonist_ratio | Inactive | NA | NA | AR | Inducible reporter | human | kidney | HEK293T
TOX21_AR_BLA_Antagonist_ratio | Inactive | NA | NA | AR | Inducible reporter | human | kidney | HEK293T
TOX21_AR_LUC_MDAKB2_Agonist | Inactive | NA | NA | AR | Inducible reporter | human | breast | MDA-kb2
TOX21_AR_LUC_MDAKB2_Agonist_3uM_Nilutamide | Inactive | NA | NA | AR | Inducible reporter | human | breast | MDA-kb2
TOX21_AR_LUC_MDAKB2_Antagonist_0.5nM_R1881 | Inactive | NA | NA | AR | Inducible reporter | human | breast | MDA-kb2
TOX21_AR_LUC_MDAKB2_Antagonist_10nM_R1881 | Inactive | NA | NA | AR | Inducible reporter | human | breast | MDA-kb2
UPITT_HCI_U2OS_AR_TIF2_Nucleoli_Agonist | Inactive | NA | NA | AR | Binding reporter | human | bone | U2OS
UPITT_HCI_U2OS_AR_TIF2_Nucleoli_Antagonist | Inactive | NA | NA | AR | Binding reporter | human | bone | U2OS
UPITT_HCI_U2OS_AR_TIF2_Nucleoli_Cytoplasm_Ratio_Agonist | Inactive | NA | NA | AR | Binding reporter | human | bone | U2OS
UPITT_HCI_U2OS_AR_TIF2_Nucleoli_Cytoplasm_Ratio_Antagonist | Inactive | NA | NA | AR | Binding reporter | human | bone | U2OS
ATG_ERa_TRANS_up | Active | 1.50 | 16.44 | ER (ESR1) | Inducible reporter | human | liver | HepG2
TOX21_ERa_BLA_Antagonist_ratio | Active | 3.32 | 22.7 | ER (ESR1) | Inducible reporter | human | kidney | HEK293T
ACEA_ER_80hr | Inactive | NA | NA | ER (ESR1) | Growth reporter | human | breast | T47D
ATG_ERE_CIS_up | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | liver | HepG2
NVS_NR_bER | Inactive | NA | NA | ER (ESR1) | Binding reporter | bovine | uterus | NA
NVS_NR_hER | Inactive | NA | NA | ER (ESR1) | Binding reporter | human | NA | NA
NVS_NR_mERa | Inactive | NA | NA | ER (Esr1) | Binding reporter | mouse | NA | NA
OT_ER_ERaERa_0480 | Inactive | NA | NA | ER (ESR1) | Binding reporter | human | kidney | HEK293T
OT_ER_ERaERa_1440 | Inactive | NA | NA | ER (ESR1) | Binding reporter | human | kidney | HEK293T
OT_ERa_EREGFP_0120 | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | cervix | HeLa
OT_ERa_EREGFP_0480 | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | cervix | HeLa
TOX21_ERa_BLA_Agonist_ratio | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | kidney | HEK293T
TOX21_ERa_LUC_VM7_Agonist | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | ovary | VM7
TOX21_ERa_LUC_VM7_Antagonist_0.1nM_E2 | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | ovary | VM7
TOX21_ERa_LUC_VM7_Antagonist_0.5nM_E2 | Inactive | NA | NA | ER (ESR1) | Inducible reporter | human | ovary | VM7
OT_ER_ERbERb_0480 | Inactive | NA | NA | ER (ESR2) | Binding reporter | human | kidney | HEK293T
OT_ER_ERbERb_1440 | Inactive | NA | NA | ER (ESR2) | Binding reporter | human | kidney | HEK293T
TOX21_ERb_BLA_Agonist_ratio | Inactive | NA | NA | ER (ESR2) | Inducible reporter | human | kidney | HEK293T
TOX21_ERb_BLA_Antagonist_ratio | Inactive | NA | NA | ER (ESR2) | Inducible reporter | human | kidney | HEK293T
OT_ER_ERaERb_0480 | Inactive | NA | NA | ER (ESR1\|ESR2) | Binding reporter | human | kidney | HEK293T
OT_ER_ERaERb_1440 | Inactive | NA | NA | ER (ESR1\|ESR2) | Binding reporter | human | kidney | HEK293T

NA = not applicable.

a Data were sourced from EPA’s CompTox Chemicals Dashboard ((U.S. EPA, 2022a), accessed November 3, 2022).

b Nonspecific responses from inducible reporter gene assays analyzed in the negative fitting direction relative to the control (“_dn”) are not presented herein.

Table E-4 ToxCast model predictions for the ER and AR pathways for PFDA^a, ^ ^b^

| Agonist AUC values (95% CI) | Antagonist AUC values (95% CI)
ER pathway | 0 (0–0.0051) | 0 (0–0.019)
AR pathway | 0 (0–0.063) | 0 (0–0.00016)

AUC = area under the curve score ranging from 0 to 1. An AUC value of 0 indicates that the chemical is inactive. CI = confidence interval.

a Data for ER and AR pathways were sourced from Judson et al. (2015) and Kleinstreuer et al. (2017), respectively.

b 95% CI for the ER activity model was sourced from a subsequent publication to the Judson et al. (2015) study (Watt and Judson, 2018).

Table E-5 Bioactivity summary for PFDA from in vitro HTS assays related to steroidogenesis^a^

Assay name | Activity call | Scaled activity | AC50 (μM) | Biological target | Assay design | Organism | Tissue | Cell line
CEETOX_H295R_11DCORT_noMTC_dn | Inactive | NA | NA | 11-Deoxycortisol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_11DCORT_noMTC_up | Inactive | NA | NA | 11-Deoxycortisol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ANDR_noMTC_dn | Inactive | NA | NA | Androstenedione | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ANDR_noMTC_up | Inactive | NA | NA | Androstenedione | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_CORTIC_noMTC_dn | Inactive | NA | NA | Corticosterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_CORTIC_noMTC_up | Inactive | NA | NA | Corticosterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_CORTISOL_noMTC_dn | Inactive | NA | NA | Cortisol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_CORTISOL_noMTC_up | Inactive | NA | NA | Cortisol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_DOC_noMTC_dn | Inactive | NA | NA | 11-Deoxycorticosterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_DOC_noMTC_up | Inactive | NA | NA | 11-Deoxycorticosterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ESTRADIOL_noMTC_dn | Inactive | NA | NA | Estradiol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ESTRADIOL_noMTC_up | Inactive | NA | NA | Estradiol | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ESTRONE_noMTC_dn | Inactive | NA | NA | Estrone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_ESTRONE_noMTC_up | Inactive | NA | NA | Estrone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_OHPREG_noMTC_dn | Inactive | NA | NA | 17alpha-hydroxypregnenolone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_OHPREG_noMTC_up | Inactive | NA | NA | 17alpha-hydroxypregnenolone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_OHPROG_noMTC_dn | Inactive | NA | NA | 17alpha-hydroxyprogesterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_OHPROG_noMTC_up | Inactive | NA | NA | 17alpha-hydroxyprogesterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_PROG_noMTC_dn | Inactive | NA | NA | Progesterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_PROG_noMTC_up | Inactive | NA | NA | Progesterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_TESTO_noMTC_dn | Inactive | NA | NA | Testosterone | inducible reporter | human | adrenal gland | H295R
CEETOX_H295R_TESTO_noMTC_up | Inactive | NA | NA | Testosterone | inducible reporter | human | adrenal gland | H295R
TOX21_Aromatase_Inhibition | Inactive | NA | NA | CYP19A1 | inducible reporter | human | breast | MCF7

NA = not applicable.

a Data were sourced from EPA’s CompTox Chemicals Dashboard (U.S. EPA, 2022a), accessed November 3, 2022).