# APPENDIX D ADVERSE OUTCOME PATHWAY/ MODE OF ACTION (AOP/MOA)-BASED APPROACH FOR EVALUATING PERFLUORODECANOIC ACID (PFDA)-INDUCED MECHANISM OF HEPATOXITY

## D.1 OBJECTIVE AND METHODOLOGY

The goal of the qualitative analysis described here is to evaluate the available mechanistic evidence for perfluorodecanoic acid (PFDA)-induced liver effects to assess the biological plausibility of effects observed in animal models and identify mechanistic pathways that are conserved across species and strains of animals and liver cell culture models and are therefore more relevant to human health. The available mechanistic and toxicological evidence was organized and evaluated in concordance with the frameworks used for mode-of-action (MOA) analysis for noncancer effects and development of adverse outcome pathways (AOP)^6^ (Edwards et al., 2016; Boobis et al., 2008; IPCS, 2007). PFDA-induced hepatic effects reported in in vivo and cell culture studies were organized according to the following levels of biological organization: molecular interactions, cellular effects, organ effects, and organism effects. The analysis described here was focused on the concordance of key events and adverse responses across species to obtain clarification on the relevance of animal studies to human health.

In addition to analyzing the available evidence published in the peer-reviewed literature, EPA also considered mechanistic evidence from in vitro high-throughput screening (HTS) assays on PFDA available from EPA's CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) ((U.S. EPA, 2022a); data retrieved on November 03, 2022). Bioactivity data from the ToxCast and Tox21 collaborative projects were also considered at the same levels of biological organization described below. A more detailed description of the HTS analysis and results is provided in Appendix E.

## D.2 PROPOSED MOA/AOP APPROACH FOR EVALUATING PFAS-INDUCED LIVER TOXICITY

The proposed MOA displayed in Figure D1 is based on molecular initiating events, key events, and adverse outcomes identified in previous mechanistic evaluations and reviews of perfluorooctane sulfonic acid (PFOS) and perfluorinated alkylated substances (PFOA) (U.S. EPA, 2024a, b; ATSDR, 2018; Li et al., 2017a; U.S. EPA, 2016a, b), which are structurally related to PFDA and among the most well-studied PFAS. Additional reviews on biological pathways associated with chemical-induced cancer and noncancer liver effects were also consulted (see citations below). A summary of the MOA is presented below.

At the molecular level, experimental studies using in vivo and cell culture models have shown that perfluorinated compounds such as PFOS and PFOA can activate several nuclear receptor pathways including the constitutive androstane receptor (CAR), the pregnane X receptor (PXR), the farnesoid X receptor (FXR), the peroxisome proliferator-activated receptor alpha (PPARα) and gamma (PPARγ), estrogen receptor alpha (ERα) and other receptor-independent cell signaling pathways (e.g., phosphatidylinositol 3-kinase-serine/threonine protein kinase (PI3K-Akt) signal transduction pathway, and the nuclear factor kappa B pathway [NFκB]) (ATSDR, 2018; Li et al., 2017a; U.S. EPA, 2016a, b). PFOS- and PFOA-induced activation of PPARα is associated with hepatocellular hypertrophy caused by peroxisome proliferation, increased peroxisomal fatty acid β oxidation and cytochrome P450 4A (CYP4A) expression and activity (U.S. EPA, 2024a, b; ATSDR, 2018; U.S. EPA, 2016a, b), and altered cholesterol metabolism (Li et al., 2017a). Increased PPARα activity can lead to oxidative stress via induction of acyl-CoA oxidase expression and activity and to H_2_O_2_ production in peroxisomes (Hall et al., 2012). Several studies have used genetically modified animal and cell culture models and immortalized human cell lines to evaluate potential PFOS or PFOA activation of the human PPARα. COS-1 cells transfected with the murine or human PPARα were responsive to PFAS exposure (U.S. EPA, 2024a, b, 2016a, b), and F1 generation PPARα-humanized mice were responsive to PFOA-induced expression responsive genes on GD 18, but unlike wild-type animals this response was not apparent on postnatal day 20 (U.S. EPA, 2016b; Takacs and Abbott, 2007). Studies using human liver cell lines or humanized animal models suggest humans are less sensitive to PPARα activation by the perfluorinated compounds PFOS and PFOA (reviewed in Li et al. (2017a) and U.S. EPA (2016a)). PPARα has also been shown to be activated by exposure to several PFAS, including PFOS, PFOA, PFNA, and PFHxS (ATSDR, 2018; Li et al., 2017a). Although PPARα is not expressed in high levels in the liver, its activation by pharmaceuticals and xenobiotic compounds has been proposed to be associated with hepatic steatosis caused by lipid accumulation (Angrish et al., 2016; Mellor et al., 2016).

As described above, exposure to perfluorinated compounds such as PFOS and PFOA has also been shown to activate other nuclear receptor and cell signaling pathways including the CAR, PXR, FXR, ERα, NFκB, and the oxidative stress responsive nuclear factor erythroid 2 related factor 2 (Nrf2) (ATSDR, 2018; Li et al., 2017a; U.S. EPA, 2016a). Furthermore, experiments using null animal models exposed to several PFAS suggest that activation of CAR/PXR occurs independently of PPARα (ATSDR, 2018; Li et al., 2017a). Previous analyses of chemical-induced hepatotoxicity suggest that activation of these cell signaling pathways in experimental models is associated with increased expression and activity of xenobiotic metabolizing enzymes (XMEs) (Joshi-Barve et al., 2015; Hall et al., 2012), formation of reactive metabolites, alterations in cellular lipid metabolism (Angrish et al., 2016), and endoplasmic reticulum damage (Joshi-Barve et al., 2015).

At the cellular level, exposure to PFAS such as PFOS and PFOA has been shown to increase reactive oxygen species production and oxidative damage to cellular macromolecules (ATSDR, 2018; Li et al., 2017a; U.S. EPA, 2016a); promote mitochondrial damage, inhibit mitochondrial function, activate mitochondrial-mediated cell death (Li et al., 2017a; U.S. EPA, 2016b); increase endoplasmic reticulum stress (U.S. EPA, 2016b); induce DNA damage (ATSDR, 2018; U.S. EPA, 2016b); disrupt intercellular gap junction communication (ATSDR, 2018); elevate production/levels of proinflammatory cytokines (U.S. EPA, 2016b); alter lipid and glucose metabolism and bile acid biosynthesis (U.S. EPA, 2024a, b, 2016a, b); and increase hepatocellular death (Li et al., 2017a; U.S. EPA, 2016a). These pathways/mechanisms are associated with toxicant-induced liver disease and can promote steatohepatitis and fibrosis (Angrish et al., 2016; Cao et al., 2016; Joshi-Barve et al., 2015; Wahlang et al., 2013).

Figure D-1 This proposed MOA is based on previous analyses on PFAS-induced (e.g., PFOA/PFOS) liver toxicity and the role of nuclear receptor pathways in hepatotoxicity.

Figure D-1. This proposed MOA is based on previous analyses on PFASinduced (e.g., PFOA/PFOS) liver toxicity and the role of nuclear receptor pathways in hepatotoxicity.

## D.3 SYNTHESIS OF MECHANISTIC STUDIES AND SUPPLEMENTAL INFORMATION FOR PFDA

As mentioned previously, mechanistic evidence from peer-reviewed studies and HTS assays from EPA's ToxCast/Tox21 database were organized and evaluated according to the proposed MOA for the noncancer liver effects associated with exposure to PFAS (see Figure D-1). The evidence consists primarily of in vitro and in vivo studies conducted in liver tissues derived from human and animal models. When available, cell-free receptor binding studies and gene reporter assays profiling different key events in receptor signaling pathways in other cell tissue models (e.g., receptor dimerization, cofactor recruitment, DNA binding, and gene transactivation) were included in the analysis to provide additional information on the activation of nuclear receptor pathways and on potential species-specific differences in receptor sensitivity relevant to the mechanisms of liver toxicity for PFDA and other PFAS.

### D.3.1 Molecular Initiating Events

As discussed below, the available studies have examined several nuclear receptor and cell signaling pathways associated with chemical-induced liver toxicity.

#### PPARα

PPARα is involved in a variety of processes, including nutrient metabolism, tissue development, cell differentiation, xenobiotic biotransformation, and inflammation (Li et al., 2017a). Induction of PPARα activity is primarily associated with increased CYP450 activity, peroxisomal proliferation, and hepatomegaly (liver enlargement) (Hall et al., 2012) and has been implicated in the mechanisms of hepatotoxicity of PFAS such as PFOS and PFOA (ATSDR, 2018; U.S. EPA, 2016a). Several experimental studies have evaluated PFDA-induced activation of PPARα in vivo in rat and mouse liver, and in human and rodent hepatocyte cell cultures. PFDA exposure was associated with increased hepatic expression of PPARα-responsive genes in Sprague-Dawley rats (NTP, 2018; Sterchele et al., 1996), C57BL/6J mice (Abe et al., 2017; Cheng and Klaassen, 2008a, b; Maher et al., 2008), and SV129 mice (Luo et al., 2017). PFDA treatment has also been shown to increase hepatic PPARα mRNA levels (Sterchele et al., 1996) and activity of the PPARα-responsive enzyme acyl-CoA oxidase in Sprague-Dawley rats (NTP, 2018). Chinje et al. (1994) exposed male Wistar rats and Harley guinea pigs to PFDA and reported increased CYP4A1 mRNA levels (indicative of PPARα activation) in rats, but no effects in guinea pigs. These findings are consistent with analyses that conclude guinea pigs, along with Syrian hamsters and nonhuman primates, are less responsive to PPARα activation than other rodent models (Corton et al., 2018; Hall et al., 2012).

Several cell culture and in vitro studies also report evidence considered supportive of the in vivo findings. PFDA exposure increased mRNA levels of PPARα and PPARα-responsive genes in rat hepatoma FaO cells (Sterchele et al., 1996). Two studies evaluated PFDA-induced effects on PPARα-responsive genes in human hepatic progenitor cells (HepaRG). One study was unable to measure activation of PPARα or other nuclear receptors because of PFDA exposure associated with cytotoxicity (100 μM) but detected gene reported activity in nonhuman primate kidney cells transfected with the mouse PPARα (COS-1) (Abe et al., 2017). The other study, which tested a lower PFDA concentration (45 μM), confirmed PPARα activation (Lim et al., 2021). Rosen et al. (2013) analyzed gene expression changes in response to PFDA treatment and reported higher transcriptional activity in cultured primary human versus mouse hepatocytes, including the induction of PPARα-dependent and PPARα-independent genes. The lower-than-expected pattern of transcriptional activity for PFDA and other PFAS in cultured primary mouse hepatocytes compared with previous in vivo studies was attributed to cell culture conditions and the absence of hepatic nonparenchymal cells (Rosen et al., 2013). The authors also noted inconsistencies in the dose-response patterns of transcriptional activity in human hepatocytes across PFAS that could be due to interindividual variation in donor cells or inherent differences in the pattern of gene expression of tested chemicals (Rosen et al., 2013). PPARα-dependent reporter gene expression was also induced after PFDA treatment in human hepatoma HepG2 cells (Rosenmai et al., 2018) and human embryonic kidney HEK293 cells (Buhrke et al., 2013). HTS assays showed induction of PPARα transactivation in HepG2 cells but no activity in a binding reporter assay for the human PPARα (see Table E-2). However, a recent in vitro study in the peer-reviewed literature reported that PFDA can bind to the human PPARα ligand binding domain, albeit with lower affinity than in the Baikal seal PPARα (Ishibashi et al., 2019). Potential interspecies differences in PPARα activation were also described by Routti et al. (2019); Wolf et al. (2012); Wolf et al. (2008), showing induction of transcriptional activity of the mouse and polar PPARα isoforms but minimal or no activity toward the human PPARα in nonhuman primate kidney cells (COS-1 and COS-7) exposed to PFDA.

Overall, the available evidence suggests that PFDA can activate hepatic PPARα in rats and mice in vivo and in cell culture models. There are inconsistencies with respect to the activation of PPARα in in vitro human models possibly due to differences in experimental design and/or potential confounding with PFDA-induced cytotoxicity. However, some evidence indicates that PFDA interacts with the human PPARα in immortalized and primary cells derived from liver tissue. The data also suggest potential species differences in the binding affinity and activity of PPARα with the human isoform being potentially less sensitive compared with other mammalian species. In vivo studies with genetically modified animals in which the gene encoding PPARα is inactivated are needed to further characterize these differences.

#### Other PPARs (PPARγ and PPARβ/δ)

Two other PPAR subtypes have been characterized, PPARγ and PPAR beta/delta (β/δ), that play an essential role in energy homeostasis and metabolism. PPARγ is known to regulate adipogenesis, lipid and glucose metabolism, and inflammatory pathways, and its hepatic upregulation has been proposed as a key mechanism in the pathogenesis of nonalcoholic fatty liver disease (NAFLD) (Al Sharif et al., 2014). PFDA-induced transactivation of human PPARγ was observed in HEK263 (Buhrke et al., 2013) and HepG2 cells (Zhang et al., 2014) and HTS results from EPA’s ToxCast/Tox21 database, which are displayed in Table E-2. PFDA also showed affinity for the human PPARγ in receptor-ligand binding assays (see Zhang et al. (2014) and Table E-2) but displayed no activity in agonist/antagonist or cofactor recruitment assays related to this receptor conducted in HEK293T cells (see Table E-2). Further, PFDA upregulated the expression of the PPARγ gene in primary human hepatocytes (Rosen et al., 2013).

PPARβ/δ is involved in fatty acid metabolism and suppression of macrophage-derived inflammation (Barish et al., 2006). Studies examining potential interaction between PFAS and PPARβ/δ are limited. In vitro evidence showed that PFDA is capable of binding to the human PPARβ/δ and activating its transcriptional activity in HEK293 cells at noncytotoxic concentrations (<100 μM) (Li et al., 2019a). In contrast, PFDA was inactive in ToxCast/Tox21 assays (see Table E-2), evaluating human PPARβ/δ transactivation in HEK293 and HepG2 cells at concentrations up to 200 μM. Differences in experimental design (e.g., reporter system) could account for discrepancies in the results.

There is in vitro evidence that suggests potential activation of other human PPAR subtypes after PFDA treatment, primarily PPARγ and possibly PPARβ/δ. Experimental studies in animals and humanized models would be critical to confirming and better characterizing the potential role of these receptors in the mechanism(s) of hepatotoxicity from PFDA exposure.

#### CAR/PXR

Chemical-induced activation of CAR and PXR leads to increased expression and activity of XMEs (Li et al., 2017a; Hall et al., 2012) and drug transport proteins (Mackowiak et al., 2018). In addition to metabolism and excretion of xenobiotic compounds (and endogenous substrates such as steroids and fatty acids), CAR/PXR-induced xenobiotic enzyme activities have been proposed to promote formation of reactive metabolites (Wang et al., 2014; Li et al., 2012), alter drug interactions (Mackowiak et al., 2018), and increase oxidative stress, immune responses, and mitochondrial disfunction (Wang et al., 2014). CAR/PXR activation can also alter lipid homeostasis and promote hepatic steatosis (Mackowiak et al., 2018; Mellor et al., 2016).

Experimental studies have evaluated PFDA-mediated activation of CAR and PXR in rodents. PFDA exposure led to increased CAR mRNA levels, nuclear translocation of CAR, and increased mRNA and/or protein levels of CAR- and PXR-responsive genes, such as Cyp2B10 and Cyp3A11, in C57BL6/6J mice (Abe et al., 2017; Cheng and Klaassen, 2008b). NTP (2018) also reported increased mRNA levels of CAR-responsive genes, Cyp1B1 and Cyp1B2, in Sprague-Dawley rats. Further evaluation of the effects of PFDA on CYP450s in genetically modified mice devoid of function of specific nuclear receptors revealed that PFDA-mediated Cyp2B10 mRNA expression is regulated by CAR and independent of PPARα, PXR or FXR (Cheng and Klaassen, 2008b). PXR was also not required for the induction of Cyp3A11 mRNA after PFDA exposure (Cheng and Klaassen, 2008b).

Cell culture studies and HTS assays from the ToxCast/Tox21 database have also evaluated PFDA-induced activation of CAR and PXR. PFDA exposure resulted in increased mRNA and protein levels of PXR but did not affect the expression of the PXR target gene, Cyp3A23, in primary rat hepatocytes (Ma et al., 2005). PXR-dependent CYP3A4 activation by PFDA was reported in HepG2 cells transfected with the human PXR (Zhang et al., 2017), and increased mRNA levels of CAR/PXR-responsive genes, CYP2B6 and CYP3A4, were detected in primary human hepatocytes after PFDA treatment (Rosen et al., 2013). In primary mouse hepatocytes, PFDA treatment had no effect on CAR-responsive genes, but according to the study authors this may have been caused by cell culture conditions and time in culture before and during exposure (Rosen et al., 2013). An additional study reported no effects on the induction of the mouse or human CAR in gene reporter assays using nonhuman primate kidney COS-1 cells but failed to assess PFDA-induced expression of CAR-responsive genes in HepaRG cells due to increased cytotoxicity after chemical exposure (100 μM) (Abe et al., 2017). Using a lower PFDA concentration (45 μM), Lim et al. (2021) showed upregulation of the CAR-target gene, CYP2B6. Gene reporter activity measured in HTS assays conducted in HepG2 cells revealed PFDA-induced activation of the human PXR in one of three assays but no activation of the human CAR across four assays (see Table E-2). PFDA also demonstrated binding activity for the human PXR (see Table E-2).

Overall, the available evidence suggests that PFDA exposure can activate the murine CAR resulting in altered levels of CYP450s in vivo and, although not all available experiments were clearly positive, PFDA appears to interact with PXR in in vitro rodent and human model systems. Future studies focusing on the potential involvement of these receptors in the mechanisms of PFDA-induced liver effects would be informative.

#### FXR

FXR is a key regulator of bile acid synthesis and lipid metabolism (Russell, 2003). Deletion of the mouse FXR gene (Nr1h4) leads to fatty liver and insulin resistance (Ma et al., 2006) and exacerbation of chemical-induced acute liver injury (Takahashi et al., 2017), while activation of FXR in response to liver injury and disease may have a protective role (Han, 2018). PFDA was evaluated in HTS from EPA's ToxCast/Tox21 database (see Appendix E for more details). No FXR activity was detected in assays related to receptor/cofactor interaction or agonist/antagonist transactivation in human embryonic kidney HEK293 cells (see Table E-2). Conversely, PFDA displayed agonist activity in a cell-free receptor-ligand binding assay and was active in one of two assays profiling transcriptional activity of this receptor in a human liver cell line (HepG2) (see Table E-2). Importantly, PFDA exhibited high potency for the human FXR compared with other nuclear receptors (e.g., PPARα/γ and CAR/PXR) on the basis of estimated effective concentrations (i.e., AC50 values) (see Figure E-3B). In summary, FXR appears to be a sensitive target of PFDA in HTS assays and thus, similar to CAR above, experiments specifically targeting the potential role of this receptor in the liver effects of PFDA would be informative.

#### Other Pathways

Additional cell signaling pathways have been evaluated in vivo and in liver cells in vitro. In Wistar rats and SV129 mice, PFDA exposure had no effects on mRNA levels of c-Jun/c-Fos (Luo et al., 2017) (Oguro et al., 1998). Similarly, PFDA exposure had no significant effects on aryl hydrocarbon receptor (AHR)-inducible P450 activity in C57BL/6J mice (Brewster and Birnbaum, 1989) or mRNA expression of AHR-responsive genes (Cyp1A1/2) in C57BL/6J mice (Cheng and Klaassen, 2008b) and HepaRG cells (Lim et al., 2021). However, PFDA increased 2, 3, 7, 8-tetrachlorodibenzo-p-dioxin (TCDD)-induced AHR transactivation in an antagonist assay conducted in mouse hepatoma Hepa 1.12cR cells (Long et al., 2013). Effects on inflammatory and oxidative/cellular stress signaling involving the nuclear factor erythroid 2 related factor 2 (Nrf2), nuclear factor kappa B pathway (NFκB), tumor necrosis factor alpha (TNFα), c-Jun-N-terminal kinase (JNK) and activating transcription factor 2 (ATF-2) were reported following PFDA exposure in rodents (see syntheses on inflammation and cellular stress in Section D.3.2 for more details).

In vitro HTS assays from ToxCast/Tox21 showed induction of target gene pathways in HepG2 and HepaRG cells (measured as gene reporter activity) (see Table E-1), including several nuclear receptors discussed previously. According to estimated AC50 values (concentration at half maximal response), gene-specific activities occurred upstream but in some cases were closely associated with responses indicative of cellular stress/cytotoxicity (see Figure E-1). Specifically, PFDA was active in all three assays measuring Nrf2 transcriptional or agonist activity but was inactive in transactivation assays for NFκB and AHR in HepG2 and HepaRG cells (see Table E-1). Induction of transcriptional activity for JUN/FOS was demonstrated in HepaRG cells but not HepG2 cells with PFDA exposure (see Table E-1).

Overall, the available experimental studies suggest that in addition to activation of PPARα and CAR/PXR nuclear receptor pathways (and possibly PPARγ and FXR on the basis of limited in vitro studies in human cells), exposure to PFDA may also promote activation of other cell signaling pathways associated with inflammatory and oxidative/cellular stress responses (see syntheses on inflammation and cellular stress in Section D.3.2 for more details).

### D.3.2 Cellular Effects

As discussed below, the available studies provide evidence on potential PFDA-induced alterations in hepatic expression and/or activity of XMEs, oxidative stress, cell and mitochondrial damage, inflammation, and alterations in liver metabolic functions.

#### Expression and Activity of XMEs

Several in vivo studies have evaluated PFDA-induced effects on the expression and activity of XMEs. In Wistar rats, PFDA exposure was associated with increased cytochrome P450 content and activity of NADPH-cytochrome c (P-450) reductase (Yamamoto and Kawashima, 1997) and decreased GST protein levels and activity (Oguro et al., 1998; Kawashima et al., 1995; Schramm et al., 1989). Furthermore, PFDA exposure altered bilirubin glucuronosyltransferase activities and bilirubin, morphine, testosterone, and naphthol glucuronidation (Arand et al., 1991). In Fischer rats, PFDA treatment resulted in decreased sulfotransferase protein levels (Witzmann et al., 1996) and microsomal carboxylesterase activity (Derbel et al., 1996). A study using SV129 mice found that PFDA exposure decreased hepatic mRNA levels of CYP450s, and organic-anion-transporting polypeptides (OATPs) involved in the bile acid synthesis and uptake, while increasing mRNA levels of UDP-glucuronosyltransferases (UGT) enzymes (Luo et al., 2017). PPARα-null mice were mostly resistant to these effects (Luo et al., 2017). Similarly, Cheng and Klaassen (2008b) reported that PFDA-mediated downregulation of hepatic bile acid uptake transporters (OATPs and the Na+-taurocholate cotransporting peptide) is notably disrupted in PPARα-null mice but not in CAR-, PXR-, Nrf2- or FXR-null counterparts. As such, PPARα appears to be involved in the modulation of metabolizing enzymes and transport mechanisms important for bile acid homeostasis.

Several in vivo studies evaluated the effects of PFDA exposure on multidrug resistance proteins, which play important roles in hepatic metabolic and detoxifying functions, including bile acid excretion (Roth et al., 2019; Yang et al., 2014). In Sprague-Dawley rats, PFDA exposure was associated with decreased mRNA and protein levels of the hepatic multidrug resistance protein 2 (Mrp2), albeit effects were not statically significant (Johnson and Klaassen, 2002). A separate study reported that PFDA exposure significantly increased Mrp2 mRNA levels in SV129 mice and that PPARα-null animals were resistant to this effect (Luo et al., 2017). Two studies using wild-type and PPARα-null mice evaluated PFDA-induced changes in hepatic levels of Mrp3 and Mrp4 (Luo et al., 2017; Maher et al., 2008). Both studies report that PFDA treatment increased Mrp4 mRNA levels in wild-type SV129 or C57BL/6J mice, but the responses in PPARα-null animals differed: Maher et al. (2008) observed that elimination of PPARα ameliorated this effect, while Luo et al. (2017) reported that PPARα-nulls were as responsive as wild-type animals. Maher et al. (2008) observed that unlike wild-type mice, PPARα-null animals were resistant to PFDA induction of Mrp3, and Luo et al. (2017) reported no exposure-related effects on Mrp3 levels in either wild-type or null animals. Luo et al. (2017) and Maher et al. (2008) used a similar dose regimen (single i.p. injection of 80 mg/kg) but Luo et al. (2017) sampled animals on day 5 post exposure whereas Maher et al. (2008) sampled animals 48 hours post exposure and test mouse strain (SV129 and C57BL/6, respectively) differed between studies. These differences in experimental model and/or design features could account for the perceived discrepancies in the results. Maher et al. (2008) also reported that Nrf2-null mice were resistant to PFDA-induced expression of Mrp3 and Mrp4, and that pretreatment with gadolinium chloride ameliorated PFDA induction of Mrp4 mRNA levels but had no effect on Mrp3. Overall, the results suggest that PPARα and other signaling pathways (i.e., Nrf2 and Kupffer cell activation) participate in PFDA-mediated disruption of hepatic efflux Mrp transporters.

A study evaluating transcriptomic changes in HepaRG cells with exposure to PFDA and other long-chain PFAS observed enrichment of gene pathways involved in phase I and phase II metabolism, transporters, bile acid metabolism, amino acid metabolism and carbohydrate metabolism (Lim et al., 2021). An increase in transcriptomic response was reported with increasing carbon chain length with PFDA being the most potent PFAS tested. Specifically with respect to transporters, PFDA exposure was associated with the upregulation of xenobiotic efflux transporters (e.g., ABCA3, ABCC3/MRP3, ABCC10/MRP7, and ABCG2/BCRP) and amino acid transporters involved in protein synthesis (e.g., SLC1A4, SLC1A5, SLC6A9, SLC7A1, SLC7A2, SLC7A5, SLC7A11, and SLC43A1), as well as the downregulation of bile acid or xenobiotic uptake transporters (e.g., SLC10A1/NTCP, SLCO2B1 and SLCO4C1). These observations are consistent with a potential compensatory mechanism against chemical-induced injury. The authors also noted that PFDA-mediated regulation of transporters appeared to be associated with the induction of Nrf2 rather than PPARα or CAR (Lim et al., 2021). Similarly, HTS ToxCast/Tox21 assays showed PFDA-mediated induction of gene pathways associated with xenobiotic metabolism and transport (i.e., CYP1A1, CYP2C19, CYP4A11, CYP4A22, ABCC3, and ABCG2, ) in HepaRG cells (see Figure E-2 and Table E-1).

The findings described above suggest that exposure to PFDA results in increased XME levels and activity in animal models, which is supported by evidence on PFDA-induced activation of the CAR/PXR signaling pathways, two key regulators of XMEs. Furthermore, evidence from experiments using null animals suggests that PPARα is important for PFDA-induced regulation of a number of XMEs and transporters involved in bile acid homeostasis (e.g., CYP450, UGT OATP, and Mrp proteins). Additional mechanisms involving Nrf2 and Kupffer cell-mediated inflammatory responses appear to also play a role in regulating the expression of hepatic transporters in response to chemical-induced toxicity. The disruption of bile acid synthesis and transport mechanisms is consistent with the observed increases in markers of hepatobiliary function/injury in mice following PFDA exposure (see synthesis discussions on Cellular Stress and Metabolic Effects, below). Further studies are necessary to clarify inconsistencies in the results described above and to characterize the specific role of PPARα, Nrf2, and other cell signaling pathways (e.g., CAR/PXR) in modulating XME expression and activity and associated downstream effects that could contribute to the observed hepatic effects of PFDA exposure.

#### Oxidative Stress

Increased production of reactive oxygen species (ROS) can lead to hepatocellular toxicity, as it can result in cellular damage (e.g., increase lipid peroxidation, protein oxidation, and oxidative DNA damage) (Joshi-Barve et al., 2015; Wahlang et al., 2013) and activation of proinflammatory cell signaling cascades (Joshi-Barve et al., 2015).

Several in vivo and cell culture studies have evaluated PFDA-induced oxidative stress. In CD-1 mice, PFDA decreased the activity of antioxidant enzymes such as total superoxide dismutase (T-SOD), catalase (CAT), and glutathione peroxidase (GPx) activities, while increasing the level of hepatic oxidative markers including ROS, thiobarbituric acid reactive substances (TBARS) and malondialdehyde (MDA) in hepatic tissue (Wang et al., 2020). Likewise, PFDA exposure increased hepatic expression of ROS-responsive genes (Maher et al., 2008; Permadi et al., 1993) and microsomal lipid peroxidation (Cai et al., 1995) in C57BL/6J mice. In Sprague-Dawley and Wistar rats, PFDA exposure consistently altered expression of ROS-sensitive proteins known to respond to increased ROS including, glutathione-S-transferase, catalase, and glutathione reductase (Chen et al., 2001; Kim et al., 1998; Glauert et al., 1992; Ikeda et al., 1985). These findings are supported by the observation that PFDA exposure results in the activation of the ROS-sensitive transcription factor, Nrf2, in C57BL/6J mice (as indicated by the increase in the hepatic expression of the Nrf2 gene marker, Nqo1) (Maher et al., 2008). Studies in PPARα-null mice determined that PFDA-mediated activation of the mouse Nrf2 was independent of PPARα (Maher et al., 2008). Moreover, PFDA was associated with an increase in oxidative DNA damage in rat liver (Huang et al., 1994; Takagi et al., 1991) in studies with repeated-dose exposure up to 54 weeks, while no alterations in oxidative DNA damage (Kim et al., 1998), lipid peroxidation (Glauert et al., 1992), or changes in cellular antioxidant levels (Glauert et al., 1992) were reported in single exposure studies in rats. Notably, induction of microsomal lipid peroxidation in mice was also achieved after repeated-dose exposure to PFDA for 2 weeks (Cai et al., 1995).

PFDA exposure induced ROS levels (Ojo et al., 2021; Wielsøe et al., 2015) and reduced intracellular glutathione (GSH) (Ojo et al., 2021) in HepG2 cells but did not affect the total cellular antioxidant capacity (Wielsøe et al., 2015).

The available evidence suggests that PFDA exposure increases ROS production in animal models and in HepG2 cells and may also promote ROS-related cellular damage (e.g., DNA oxidation and lipid peroxidation) in rodent species after prolonged or repeated exposure. The specific involvement of Nrf2 and other cell signaling pathways in PFDA-induced ROS and potential effects on cellular antioxidant capacity and oxidative cellular and tissue damage with prolonged chemical exposure remains to be elucidated.

#### Mitochondrial Damage

Mitochondrial damage is a mechanism associated with toxicant-induced alterations in hepatocellular lipid balance (Angrish et al., 2016) and increased liver toxicity (Wahlang et al., 2013). Damage to mitochondria caused by oxidative stress, attenuation in mitochondrial transmembrane potential, and alterations in membrane permeability, electron transport, and calcium fluxes are considered stimuli that induce hepatic steatosis (Kaiser et al., 2012) and mitochondrial-mediated liver cell death (Li et al., 2017a; Cao et al., 2016).

Several in vivo studies using different animal species and strains have evaluated PFDA-induced responses in hepatic mitochondria. In Sprague-Dawley rats, exposure to PFDA led to reduced cytochrome c oxidase activity (Harrison et al., 1988) and increased mitochondrial swelling (Harrison et al., 1988), a response that can lead to disruption of the mitochondrial membrane (Jaeschke et al., 2012). Consistent with this, PFDA exposure led to increased swelling and structural alterations in liver mitochondria in CF-1 mice, Fischer rats, Syrian hamsters, and guinea pigs; responses varied across species with rats being most sensitive (Van Rafelghem et al., 1987). In C57BL/6J mice and Fischer rats, PFDA treatment caused alterations in mitochondrial protein content and increased mitochondrial enzyme activity (Permadi et al., 1993); (Witzmann and Parker, 1991; Kelling et al., 1987). In vitro studies reported that isolated rat liver mitochondria exposed to PFDA display uncoupling of electron transport and oxidative phosphorylation (Langley, 1990) and induction of mitochondrial permeability transition (Wallace et al., 2013). In primary Sprague-Dawley rat hepatocytes, PFDA treatment resulted in decreased mitochondrial metabolic functions (Vanden Heuvel et al., 1991). In vitro HTS data showed changes in mitochondrial mass but no effects on mitochondrial membrane potential in HepG2 cells after PFDA exposure (see Table E-1).

Overall, in vivo and in vitro studies suggest that PFDA exposure disrupts hepatic mitochondrial proteins, integrity and function, and some of the observed effects appeared to be conserved across different species of animals, including Syrian hamsters and guinea pigs, known to be low PPARα responders compared with other rodent models (Corton et al., 2018; Hall et al., 2012). Additional studies assessing the potential mitochondrial effects of PFDA in human primary and immortalized liver cells would help clarify the potential human relevance and essentiality of the apparent PFDA-induced disruptions of mitochondrial pathways in PFDA-induced hepatotoxicity.

#### Inflammation

Hepatic inflammation is a mechanism associated with toxicant-induced liver injury (Angrish et al., 2016; Wahlang et al., 2013). Activated macrophages and Kupffer cells produce cytokines (e.g., TNFα, interleukin[IL]-6 and IL-10) that activate hepatic stellate cells and contribute toxicant-induced liver damage (Joshi-Barve et al., 2015; Malhi and Gores, 2008).

PFDA-induced markers of hepatic inflammation and related mechanisms were evaluated in studies using rodent models. PFDA increased hepatic and/or serum protein levels of the proinflammatory cytokine TNFα in C57BL/6J mice (Maher et al., 2008), CD-1 mice (Wang et al., 2020), and Fisher-344 rats (Adinehzadeh and Reo, 1998). Induction of hepatic TNF-α levels were accompanied by increases in other proinflammatory cytokines such as IL-1β, IL-18, and IL-6 and increases in Nod-like receptor family, pyrin domain containing 3 (NLRP3) inflammasome activation markers such as NLRP3, adaptor apoptosis-associated speck-like protein (ASC) and caspase-1 in CD-1 mice (Wang et al., 2020). Maher et al. (2008) also reported that pretreatment with gadolinium chloride, an anti-inflammatory agent that suppresses Kupffer cell responses, ameliorated induction of TNFα levels in PFDA-exposed C57BL/6J mice. These results suggest that Kupffer cells may play a role in pro-inflammatory responses following PFDA exposure. Another study evaluated the involvement of PPARα on PFDA-induced responses related to hepatic inflammation. Luo et al. (2017) reported that exposure to PFDA-induced anti-inflammatory responses such as increased IL-10 mRNA levels and decreased phosphorylation of NFκB in SV129 mice and that these effects did not occur in exposed PPARα-null animals. Hepatic TNFα and IL-6 mRNA levels were unaffected by exposure regardless of the genetic background of the animals. Similarly, Li et al. (2022b) showed enrichment of gene pathways associated with anti-inflammatory responses in the liver of female C57BL/6J mice exposed to PFDA. Specifically, mRNA expression of cytokines IL-1β and IL-18, caspase-1, inflammasome-related genes (NLRP1, NLRP3, and NLRC4), and key regulators of inflammasome assembly (e.g., cellular inhibitor of apoptosis 2 [cIAP2]) were suppressed. The data also showed inhibition of T helper cell type 1 (Th1) differentiation in mouse livers treated with PFDA.

The inconsistent responses on TNFα levels of Luo et al. (2017) versus Maher et al. (2008), Adinehzadeh and Reo (1998), and Wang et al. (2020) may have been due to differences in experimental design. Adinehzadeh and Reo (1998) and Maher et al. (2008) measured protein levels 24 and 48 hours, respectively, after a single dose of 50–80 mg/kg via i.p. injection, whereas Luo et al. (2017) measured transcription (i.e., mRNA levels) on day 5 after a single i.p. injection of 80 mg/kg. The negative response on TNFα in the Luo et al. (2017) study is consistent with the observed anti-inflammatory response (i.e., inhibition NFκB and IL-10) and may reflect a compensatory mechanism following initial acute hepatic injury (Luo et al., 2017). Furthermore, Wang et al. (2020) evaluated protein levels of TNFα after oral administration of PFDA (13 mg/kg) for 12 days, demonstrating induction of TNF-α and other pro-inflammatory markers with sustained PFDA exposure.

In summary, although uncertainties remain, PFDA exposure appears capable of promoting both pro- and anti-inflammatory responses in rodents, and PPARα may be involved in some of these effects.

#### Cellular Stress

Several in vivo studies have evaluated markers of cellular stress after exposure to PFDA. As described in the main document for liver effects in animals (see Section 3.2.1), short-term oral exposure to PFDA has been shown to promote degenerative changes such as necrosis (Frawley et al., 2018; NTP, 2018) and increase in serum biomarkers of hepatocyte damage in Sprague-Dawley rats (NTP, 2018) and CD-1 mice (Wang et al., 2020). Liver cell necrosis can promote steatohepatitis and fibrosis by exacerbating tissue damage via increased release of cellular contents that in turn trigger proinflammatory responses and death of neighboring hepatocytes (Cattley and Cullen, 2018; Joshi-Barve et al., 2015). One study using Wistar rats evaluated PFDA-induced effects on cytoskeletal proteins and reported no exposure-related alterations (Witzmann and Parker, 1991). Additional effects indicative of cell damage/stress include PFDA-induced disruptions to the endoplasmic reticulum in the livers of Fischer or Sprague-Dawley rats, CD-1 mice, Syrian hamsters, and Guinea pigs (Harrison et al., 1988; Van Rafelghem et al., 1987), and dysregulation in intercellular gap junctions in Fischer rat and WB-F344 liver epithelial cells (Sovadinova et al., 2015). Wang et al. (2020) also reported increased expression of proapoptotic protein markers, Bax and cleaved caspase-3, in the liver of CD-1 mice exposed to PFDA. Furthermore, PFDA exposure was associated with increases in serum markers of hepatocyte and biliary damage (ALT, AST, and ALP) in wild-type SV129 mice that corresponded with the activation of responses indicative of cellular stress signaling, including phosphorylation of JNK and its downstream target, ATF-2 (Luo et al., 2017). Notably, PPARα-null animals did not show these effects (Luo et al., 2017).

Cell viability and DNA damage were not affected in HepG2 cells exposed to PFDA concentrations of up to 100 μM across two studies (Rosenmai et al., 2018; Wielsøe et al., 2015) but three other studies reported that PFDA induced cytotoxicity in HepG2 cells in a concentration-dependent manner (effective concentrations causing 50% cytotoxicity [IC_50_] were 14.10–15 μM) (Ojo et al., 2021; Ojo et al., 2020; Buhrke et al., 2013). Similarly, PFDA elevated markers of cellular stress and cytotoxicity in HTS assays conducted in HepG2 cells at higher concentrations (AC50 values ranging from 106.54 to 122.76 μM). PFDA-induced cytotoxicity was also reported in HepaRG cells (see (Abe et al., 2017) and Table E-1 of the ToxCast/Tox21 data summary), primary rat and human hepatocytes (Rosen et al., 2013), immortalized human fetal liver cells (HL-7702) (Hu et al., 2014).

Overall, the available evidence suggests that PFDA exposure increases hepatocyte cytotoxicity in in vitro and in vivo animal models, including species considered less sensitive to PPARα activation (i.e., Syrian hamsters and Guinea pigs). Studies using null animals suggest that stress responses related to disruption of bile acid homeostasis in mice may be mediated, at least in part, by PPARα. However, the potential involvement of other cellular signaling pathways in PFDA-induced liver cell stress has not been investigated.

#### Metabolic Effects

Toxicant-induced alterations in hepatocyte function can result in abnormal metabolism and accumulation of cholesterol, fatty acids and triglycerides, and exacerbate effects caused by steatosis (Angrish et al., 2016), which in turn may increase susceptibility to other insults or progress to steatohepatitis (Yang et al., 2014; Wahlang et al., 2013).

PFDA-induced effects on liver metabolic function have been evaluated in multiple rodent models. In Wistar, Fischer, and Sprague-Dawley rats PFDA exposure was associated with alterations in lipid composition (Adinehzadeh et al., 1999; Yamamoto and Kawashima, 1997; Olson and Andersen, 1983), fatty acid transport (Vanden Heuvel et al., 1993) and metabolism (Reo et al., 1994; Davis et al., 1991); and increased fatty acid and triglyceride accumulation (Kudo and Kawashima, 2003; Adinehzadeh and Reo, 1998; Kawashima et al., 1995; Sterchele et al., 1994; Harrison et al., 1988; Van Rafelghem et al., 1988). Rat studies have also reported increased hepatic levels of cholesterol (Kawashima et al., 1995), bilirubin, and bile acids (NTP, 2018); decreased microsomal electron transport (Kawashima et al., 1995; Van Rafelghem and Andersen, 1988); alterations in hepatic cholesterol metabolism (Davis et al., 1991); glucose transport (Goecke-Flora et al., 1995) and metabolism (Goecke et al., 1994); and decreased albumin levels (NTP, 2018; Witzmann and Parker, 1991). PFDA also increases peroxisomal proliferation (Van Rafelghem et al., 1987), activity of responsive enzymes such as acyl-CoA oxidases (NTP, 2018; Kim et al., 1998; Huang et al., 1994; Borges et al., 1993; Vanden Heuvel et al., 1993; Borges et al., 1992; Glauert et al., 1992; Intrasuksri and Feller, 1991; Kozuka et al., 1991a; Borges et al., 1990), and β-oxidation (Kudo and Kawashima, 2003; Kudo et al., 2000; Adinehzadeh et al., 1999; Kawashima et al., 1995; Kozuka et al., 1991b), which are consistent with the evidence of PPARα activation in experimental animal models (see synthesis on Molecular Initiating Events above). As mentioned previously, PPARs, including PPARα, regulate genes involved in lipid and cholesterol metabolism and promote β-oxidation of fatty acids (Xu et al., 2005). The findings from in vivo studies are supported by cell culture studies using primary rat hepatocytes that report alterations in fatty acid metabolism (Vanden Heuvel et al., 1991) and increased peroxisomal β–oxidation (Kudo et al., 2000).

Mice exposed to PFDA also demonstrate alterations in hepatic metabolic functions. PFDA exposure increased activity of fatty acid metabolizing enzymes (Permadi et al., 1993) and increased hepatic lipid accumulation in C57BL/6J mice (Brewster and Birnbaum, 1989), an initial manifestation of fatty liver disease that may progress to fibrosis (Wahlang et al., 2013). PFDA exposure caused alterations in the levels of bile acid metabolizing enzymes and transporters and increased serum levels of several indicators of cholestasis (including bile acids and their components and bilirubin) in mice (Luo et al., 2017; Maher et al., 2008) but PPARα-null animals were resistant to these effects (Luo et al., 2017). Finally, Van Rafelghem et al. (1987) reported extensive hepatic lipid vacuolization in hamsters and guinea pigs (and to a lesser extent in rats or mice) after PFDA treatment.

Studies examining PFDA-mediated liver metabolic effects in human models are mostly lacking. A study by Zhang et al. (2013) showed binding affinity toward the human liver fatty acid protein by multiple PFAS, including PFDA, which may disrupt fatty acid uptake and transport. More recently, Wang et al. (2022) showed increases in triglyceride content and accumulation in HepG2 cells in a concentration-dependent manner after PFDA treatment. Further, the authors demonstrated that PFDA can promote adipogenesis in vitro by activating the NLRP3 inflammasome-mediated sterol regulatory element binding transcription factor 1 (SREBP1) pathway. Similar results were observed in 3-T3-Li murine white preadipocytes treated with PFDA. NLRP3 inflammasome induction has also been demonstrated in in vivo rodent models (see section on inflammation above for more details) with PFDA and has previously been linked to metabolic impairment in human and animal studies (Oh et al., 2021; Traba et al., 2015).

The available evidence suggests that PFDA exposure alters liver metabolic functions across multiple rodent species, and in limited human in vitro studies. Studies using genetically modified animals suggest that PFDA-induced disruption of bile acid homeostasis is at least partially mediated by PPARα. More studies are needed to understand the specific role that PPARα and other cell signaling pathways play in PFDA-induced alterations in liver metabolic functions involving bile acid, glucose, lipid, and cholesterol metabolism and under what conditions these alterations might lead to steatohepatitis and other liver pathologies in humans following prolonged chemical exposure.

### D.3.3 Organ-Level Effects

Animal toxicity studies via the oral route have reported effects on histological and clinical markers and organ weight measures, which are indicative of adverse responses in the liver. These include changes in the incidence of hepatocellular necrosis, serum biomarkers of hepatobiliary and liver damage and increased liver weights (see synthesis of Animal studies in section 3.2.1 of the Toxicological Review). A study by (NTP, 2018) compared liver effects in rats after short-term exposure between PFDA (and other PFAS) and Wyeth-14, 643, which was used as a positive control for PPARα activation. Much like PFDA, Wyeth-14, 643 caused increases in liver weights, changes in liver biomarkers in the blood and hepatocyte hypertrophy; however, no evidence of necrosis or other degenerative lesions were associated with Wyeth-14, 643 exposure. The findings provide support for the hypothesis that some PFDA-induced liver responses are mediated by mechanisms independent of PPARα.

Additional evidence of PFDA-induced liver weight changes from i.p. injection studies is described herein. Several studies using rats and mice support increases in liver weight following PFDA exposure (Abe et al., 2017; Luo et al., 2017; Maher et al., 2008; Kim et al., 1998; Chen et al., 1994; Chinje et al., 1994; Borges et al., 1993; Borges et al., 1992; Kozuka et al., 1991b; Borges et al., 1990; Brewster and Birnbaum, 1989; Schramm et al., 1989; Van Rafelghem and Andersen, 1988; Kelling et al., 1987; Van Rafelghem et al., 1987; Kelling et al., 1986; Powers and Aust, 1986; Ikeda et al., 1985; Olson and Andersen, 1983). One study in particular used wild-type and PPARα-null mice and reported that PFDA exposure led to increases in liver weight regardless of the genetic background of the exposed animals (Luo et al., 2017). Two other studies evaluated PFDA-induced effects in guinea pigs and Syrian hamsters. In guinea pigs, exposure to PFDA did not have a significant impact on relative liver weight (Chinje et al., 1994; Van Rafelghem et al., 1987), whereas in Syrian hamsters, treatment was associated with increased liver weight (Van Rafelghem et al., 1987). As described above, guinea pigs and Syrian hamsters are less responsive to PPARα activation when compared with other rodent models. However, the observation that PFDA exposure caused increases in liver weights in Syrian hamsters and PPARα-null mice suggests that other cell signaling pathways may be contributing to PFDA-induced hepatomegaly in hamsters.

Overall, the available evidence from in vivo studies reports that PFDA exposure results in organ-level effects, such as increases in liver weights that are consistently observed across multiple species and may be mediated, at least in part, by PPARα-independent mechanisms.

6 Although the World Health Organization (WHO)-International Programme on Chemical Safety (IPCS)-MOA and the Organization for Economic Co-operation and Development (OECD)-AOP frameworks are similar in the identification and analysis of key events following modified Bradford-Hill criteria (Meek et al., 2014), AOPs are chemically agnostic, whereas MOA analyses are intended to inform health assessments of individual (or groups of) chemical(s) (Edwards et al., 2016).