# APPENDIX C BENCHMARK DOSE MODELING RESULTS

## C.1 BENCHMARK DOSE MODELING RESULTS FROM HUMAN STUDIES

The endpoints selected for benchmark dose (BMD) modeling include decreased serum antibody concentrations (Budtz-Jørgensen and Grandjean, 2018a; Grandjean et al., 2012) and decreased birth weight (Luo et al., 2021; Yao et al., 2021; Wikström et al., 2020; Valvi et al., 2017; Lenters et al., 2016). The internal doses reported in the human studies were used in the BMD modeling and then converted to human equivalent doses (HEDs) using the estimated human clearance as described in Section 3.1.7 of the main document, the modeling results are presented in this appendix.

### C.1.1 Benchmark Dose Modeling Approaches or Immune Effects

#### Modeling Results for Decreased Tetanus Antibody Concentrations at 7 Years of Age and PFDA Measured at 5 Years of Age

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of perfluorodecanoic acid (PFDA) measured at age 5 years, against log_2_-transformed antitetanus antibody concentrations measured at the 7-year-old examination controlling for sex, exact age at the 7-year-old examination, and booster type at age 5 years. Models were evaluated with additional control for perfluorooctane sulfonic acid (PFOS) (as log_2_[PFOS]) and perfluorinated alkylated substances (PFOA) (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model, a piecewise-linear model with a knot at the median PFDA concentration, and a logarithmic function. The logarithmic functions fit no better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). The piecewise-linear model did not fit better than the linear model for the PFDA exposure without adjustment for PFOS and PFOA using a likelihood ratio test (p = 0.51; see Budtz-Jørgensen and Grandjean (2018a) Table 3), or for the model that did adjust for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.40). The U.S. Environmental Protection Agency (EPA) used the linear model results that were the best fitting of the three models.

Table C-1 summarizes the results from Budtz-Jørgensen and Grandjean (2018b) for PFDA at age 5 years and tetanus antibodies at age 7 years. These regression coefficients (β), their standard errors (SE), p-values, and the 90% lower confidence bounds were provided by Budtz-Jørgensen and Grandjean (2018b).

Table C-1 Results specific to the slope from the linear analyses of PFDA measured in serum at age 5 years and log_2_(tetanus antibody concentrations) measured at age 7 years in a single-PFAS model and in a multi-PFAS model from (Budtz-Jørgensen and Grandjean, 2018b)

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum | SE(β) ng/mL in serum | Slope (β) fit | Lower bound slope (β_LB_) per ng/mL in serum
PFDA at age 5 yr | Linear | No | −1.55 | 0.602 | p = 0.01 | −2.55
PFDA at age 5 yr | Linear | Yes | −0.98 | 0.681 | p = 0.15 | −2.10

Interpretation of results in Table C-1:

- PFDA is a significant predictor in the single-PFAS model (β = −1.55; p = 0.01).
- Effects of PFDA in the single-PFAS model are attenuated when log2[PFOS] and log2[PFOA] are included in the model (β = −0.98; p = 0.15).
- The point estimate results for PFDA (β) in the single-PFAS model are potentially confounded by PFOS and/or PFOA since there was a 37% reduction in the effect size for PFDA from −1.55 to −0.98 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA were confounders of the PFDA effect and controlling for those coexposures removed confounding.
  ○ Another possibility is that controlling for coexposures like PFOS and PFOA actually induced confounding (Weisskopf et al., 2018; Weisskopf and Webster, 2017).
  - The reasons for the change in main effect size for PFDA are unknown. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFDA.
- However, the lower bound on the point estimate (β_LB_) for the single-PFAS is 18% lower than the multi-PFAS model estimate for PFDA.
  ○ The definition of the RfD, which is based on the β_LB_, includes allowing for an order of magnitude (10-fold or 1, 000%) uncertainty in the estimate, and the uncertainty for potential confounding in the BMD from including or excluding PFOS and PFOA here is about 37%, while the uncertainty for potential confounding in the BMDL is about 18%.

Additional details about other potential confounders follows:

- PFNA is not a significant predictor in the single-PFAS model (β = −0.227; p = 0.16) and the association is just 15% of the strength of the PFDA association from (Budtz-Jørgensen and Grandjean, 2018b), thus PFNA could not have been a meaningful confounder even though PFNA was highly correlated with PFDA (r = 0.78) (Grandjean et al., 2012)).
- PCBs had a weak correlation with PFDA (r = 0.14; Grandjean et al. (2012)) meaning that PCBs could not have been a meaningful confounder of the PFDA effect estimate.

#### Selection of the Benchmark Response

The BMD approach involves dose-response modeling to obtain BMDs, i.e., dose levels corresponding to specific response levels near the low end of the observable range of the data and the lower limit of the BMD (BMDLs) to serve as potential PODs for deriving quantitative estimates below the range of observation (U.S. EPA, 2012). Selecting a BMR to estimate the BMDs and BMDLs involves making judgments about the statistical and biological characteristics of the dataset and about the applications for which the resulting BMDs and BMDLs will be used. An extra risk of 10% is recommended as a standard reporting level for quantal data for toxicological data. Biological considerations may warrant the use of a BMR of 5% or lower for some types of effects as the basis of the POD for a reference value. However, a BMR of 1% has typically been used for quantal human data from epidemiological studies (U.S. EPA, 2012), although this is more typically used for epidemiological studies of cancer mortality within large cohorts of workers that can support the statistical estimation of small BMRs.

A blood concentration for tetanus antibodies of 0.1 IU/mL is sometimes cited in the tetanus literature as a “protective level.” (Grandjean et al., 2017) noted that the Danish vaccine producer, Statens Serum Institut, recommended the 0.1 IU/mL “cutoff" level “to determine whether antibody concentrations could be considered protective”; and Galazka and Kardymowicz (1989) mentions the same concentration but Galazka et al. (1993) argues:

"The amount of circulating antitoxin needed to ensure complete immunity against tetanus is not known for certain. Establishment of a fixed level of tetanus antitoxin does not take into consideration variable conditions of production and adsorption of tetanus toxin in the anaerobic area of a wound or a necrotic umbilical stump. A given serum level could be overwhelmed by a sufficiently large dose of toxin. Therefore, there is no absolute protective level of antitoxin and protection results when there is sufficient toxin-neutralizing antibody in relation to the toxin load (Passen and Andersen, 1986).”

Without a clear definition of an adverse effect for a continuous endpoint like antibody concentrations, a default BMR of 1-SD change from the control mean may be selected, as suggested in EPA's draft Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). As noted above, a lower BMR can also be used if it can be justified on a biological and/or statistical basis. Figure C-1 replicates a figure in the technical guidance (page 23; (U.S. EPA, 2012) to show that in a control population in which 1.4% are considered to be at risk of having an adverse effect, a downward shift in the control mean of 1-SD results in an approximately 10% extra risk of being at risk of having an adverse effect.

Figure C-1 Difference in population tail probabilities resulting from a one-standard deviation shift in the mean from a standard normal distribution, illustrating the theoretical basis for a baseline BMR of 1 SD.

Statistically, the technical guidance additionally suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as antitetanus antibody concentrations prevent against tetanus, which is a rare, but severe and sometimes fatal infection, with a case-fatality rate in the United States of 13% during 2001–2008 (Liang et al., 2018). The case-fatality rate can be more than 80% for early lifestage cases (Patel and Mehta, 1999). Selgrade (2007) suggests that specific immunotoxic effects observed in children may be broadly indicative of developmental immunosuppression impacting their ability to protect against a range of immune hazards—which could be a more adverse effect than just a single immunotoxic effect. Thus, decrements in the ability to maintain effective levels of tetanus antitoxins following immunization may be indicative of wider immunosuppression in these children exposed to PFDA. By contrast, a BMR of 1-SD may be more appropriate for an effect that would be considered “minimally adverse.” A BMR smaller than ½ SD is generally selected for severe effects (e.g., 1% extra risk of cancer mortality); decreased antibody concentrations offer diminished protection from severe effects but are not themselves severe effects.

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a one-SD change in the distribution of log_2_(tetanus antibody concentrations), and ½-SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(tetanus antibody concentrations) at age 7 years was estimated from the distributional data presented in Grandjean et al. (2012), as follows: The interquartile range (IQR) of the tetanus antibody concentrations at age 7 years in IU/mL was (0.65, 4.6). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−0.62,2.20). Assuming that these log_2_-transformed values are reasonably represented by a normal distribution, the width of the IQR is approximately 1.35 SDs. Thus, SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (2.20 - (−0.62))/1.35 = 2.09 log_2_(IU/mL). To show the impact of the BMR on these results, Table C-2 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

While there was no clear definition of the size of an adverse effect for a continuous endpoint like antibody concentrations, the value of 0.1 IU/mL is sometimes cited. As a check, EPA evaluated how much extra risk would have been associated with a BMR set at a cutoff value of 0.1 IU/mL. Using the observed distribution of tetanus antibodies at age 7 years in log_2_(IU/mL), EPA calculated that 2.8% of those values would be below the cutoff value of 0.1 IU/mL which is −3.32 log_2_(IU/mL). A BMR of ½ SD resulted in 7.9% of the values being below that cutoff, which is 5.1% extra risk and demonstrates the generic guidance that a BMR of ½ SD can provide a reasonably good estimate of 5% extra risk. Figure C-2 shows an example of this.

Figure C-2 Difference in population tail probabilities resulting from a ½-standard deviation shift in the mean from an estimation of the distribution of log_2_(tetanus antibody concentrations at age 7 years).

Figure C-2. Difference in population tail probabilities resulting from a ½-standard deviation shift in the mean from an estimation of the distribution of log2(tetanus antibody concentrations at age 7 years).

To provide context for the size of the two BMRs evaluated, the BMR (½ SD) is used in the derivation of the BMDL. The SD of the log_2_(tetanus antibody concentration in IU/mL) is 2.09 log_2_(IU/mL), and thus ½ SD is 1.05 log_2_(IU/mL). Exponentiating this to the natural scale, a ½-SD change in log_2_(IU/mL) is equivalent to a 2.07-IU/mL change (i.e., 2^1.05^). The interquartile range of PFDA in the serum of 5-year-olds was (0.65 IU/mL, 4.60 IU/mL), so a ½-SD change of 2.07 IU/mL is approximately equal to half the interquartile rage or about a 25% change in the distribution.

Table C-2 BMDs and BMDLs for effect of PFDA at age 5 years on antitetanus antibody concentrations at age 7 years using a BMR of ½-SD change in log_2_(tetanus antibodies concentration) and a BMR of 1-SD change in log_2_(tetanus antibodies concentration)

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL in serum); β = −1.55 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −2.55 per ng/mL | BMD (ng/mL in serum); β = −0.98 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −2.10 per ng/mL
½ SD | 0.673 | 0.411 ^a^ | 1.067 | 0.497
1 SD | 1.346 | 0.821 | 2.135 | 0.994

a Denotes the selected POD.

The lowest serum PFDA concentration measured at age 5 years was 0.05 ng/mL, the 5th percentile was 0.1 ng/mL, and the 10th percentile was 0.2 ng/mL (Grandjean and Bateson, 2021), so the estimated BMDL for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is above the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFDA well.

The BMD_½ SD_ estimate from the multi-PFAS models is 59% higher than the BMD_½ SD_ estimate from the models with just PFDA, and the BMDL_½ SD_ estimate is 21% higher. The change in BMD estimates may or may not reflect control for any potential confounding of the regression effect estimates. While which PFAS model provided a “better" estimate of the point estimate of the effect of PFDA is not clear, the two BMDL_½ SD_ estimates are similar (0.411 ng/mL vs. 0.497 ng/mL) and EPA advanced the derivation on the basis of results that did not control for PFOS and PFOA because this model appeared to fit PFDA better (p = 0.01 vs. 0.15) and there was low uncertainty due to potential confounding in the BMDL. However, confidence was somewhat diminished by the potential confounding in the main effect—even though there was low confounding of the BMDL. Overall confidence in the BMDLs for tetanus was judged medium.

For immunotoxicity related to tetanus associated with PFDA exposure measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL_½ SD_ of 0.411 ng/mL in serum.

#### Modeling Results for Decreased Diphtheria Antibody Concentrations at 7 Years of Age and PFDA Measured at 5 Years of Age

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFDA measured at age 5 years, against log_2_-transformed antidiphtheria antibody concentrations measured at the 7-year-old examination controlling for sex, exact age at the 7-year-old examination, and booster type at age 5 years. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model of PFDA, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions fit no better than the piecewise-linear functions (Budtz-Jørgensen and Grandjean, 2018a). The piecewise-linear model fit no better than the linear model for the PFDA exposure without adjustment for PFOS and PFOA using a likelihood ratio test (p = 0.55; see Budtz-Jørgensen and Grandjean (2018a) Table 3), or for the model that did adjust for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.73). Table C-3 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for diphtheria in this exposure window. These regression coefficients (β), their standard errors (SE), p-values, and the 90% lower confidence bounds were provided by (Budtz-Jørgensen and Grandjean, 2018b).

Table C-3 Results specific to the slope from the linear analyses of PFDA in serum measured at age 5 years and log_2_(diphtheria antibodies) measured at age 7 years from Table 1 in a single-PFAS model and in a multi-PFAS model from (Budtz-Jørgensen and Grandjean, 2018b)

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum | SE(β) ng/mL in serum | Slope (β) fit | Lower bound slope (β_LB_) per ng/mL in serum
PFDA at age 5 yr | Linear | No | −0.894 | 0.561 | p = 0.11 | −1.82
PFDA at age 5 yr | Linear | Yes | −0.297 | 0.635 | p = 0.64 | −1.35

Interpretation of results in Table C-3:

- PFDA is a nonsignificant predictor in the single-PFAS model (β = −0.894; p = 0.11).
- Effects are attenuated when log_2_[PFOS] and log_2_[PFOA] are included in the model (β = −0.297; p = 0.64).
- The point estimate results for PFDA are potentially confounded by PFOS and/or PFOA since there was a 67% reduction in the effect size for PFDA from −0.894 to −0.297 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA were confounders of the PFDA effect and controlling for those coexposures removed confounding.
  ○ Another possibility is that controlling for coexposures like PFOS and PFOA induced confounding (Weisskopf et al., 2018; Weisskopf and Webster, 2017).
  ○ The reasons for the change in main effect size for PFDA are unknown. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFDA.
- However, the lower bound on the point estimate (β_LB_) for the single-PFAS model is 26% lower than the multi-PFAS model estimate for PFDA.
  ○ The definition of the RfD, which is based on the β_LB_, includes allowing for an order of magnitude (10-fold or 1, 000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including or excluding PFOS and PFOA here is about 67%, while the uncertainty for potential confounding in the BMDL is about 35%.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a 1-SD change in the distribution of log_2_(diphtheria antibody concentrations), and ½-SD change in the distribution of log_2_(diphtheria antibody concentrations). A blood concentration for diphtheria antibodies of 0.1 IU/mL is sometimes cited in the diphtheria literature as a “protective level.” Grandjean et al. (2017) noted that the Danish vaccine producer, Statens Serum Institut, recommended the 0.1 IU/mL “cutoff’ level; and Galazka et al. (1993) mentions the same concentration), but Galazka et al. (1993) argues:

"However, it has also been shown that there is no sharply defined level of antitoxin that gives complete protection from diphtheria (Ipsen, 1946). A certain range of variation must be accepted; the same degree of antitoxin may give an unequal degree of protection in different persons. Other factors may influence the vulnerability to diphtheria including the dose and virulence of the diphtheria bacilli and the general immune status of the person infected (Christenson and Böttiger, 1986). Thus, an antibody concentration between 0.01 and 0.09 IU/ml may be regarded as giving basic immunity, whereas a higher titer may be needed for full protection. In some studies that used in vitro techniques, a level of 0.1 IU/ml was considered protective (Cellesi et al., 1989; Galazka and Kardymowicz, 1989).”

Statistically, the technical guidance suggests that studies of developmental effects can support lower BMRs. Biologically, a BMR of ½ SD is a reasonable choice as antidiphtheria antibody concentrations prevent against diphtheria, which is very rare in the United States but can cause life-threatening airway obstruction or cardiac failure (Collier, 1975). Among 13 cases reported in the United States during 1996–2016, no deaths were mentioned (Liang et al., 2018). However, diphtheria remains a potentially fatal disease in other parts of the world. (Galazka et al., 1993) mentions a case-fatality rate of 5%–10%) and PFDA-related changes in antidiphtheria antibody concentrations cannot be considered “minimally adverse, " given the historic lethality of diphtheria in the absence of vaccination. Selgrade (2007) suggests that specific immunotoxic effects observed in children may be broadly indicative of developmental immunosuppression impacting their ability to protect against a range of immune hazards—which could be a more adverse effect that just a single immunotoxic effect.

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a 1-SD change in the distribution of log_2_(diphtheria antibody concentrations) as a standard reporting level, and ½-SD change in the distribution of log_2_(diphtheria antibody concentrations). The SD of the log_2_(diphtheria antibody concentrations) at age 7 years was estimated from the distributional data presented in Grandjean et al. (2012) as follows: the interquartile range (IQR) of the diphtheria antibody concentrations at age 7 years in IU/mL was (0.4, 1.6). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−1.32, 0.68). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (0.68 - (−1.32))/1.35 = 1.48 log_2_(IU/mL). To show the impact of the BMR on these results, Table C-4 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table C-4 BMDs and BMDLs for effect of PFDA at age 5 years on antidiphtheria antibody concentrations at age 7 years using a BMR of ½-SD change in log_2_(diphtheria antibodies concentration) and a BMR of 1-SD log_2_(diphtheria antibodies concentration)

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL in serum); β = −0.894 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −1.82 per ng/mL | BMD (ng/mL in serum); β = −0.297 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −1.35 per ng/mL
½ SD | 0.827 | 0.407 ^a^ | 2.488 | 0.550
1 SD | 1.655 | 0.813 | 4.976 | 1.100

a Denotes the selected POD.

The lowest serum PFDA concentration measured at age 5 years was 0.05 ng/mL, the 5th percentile was 0.1 ng/mL, and the 10th percentile was 0.2 ng/mL (Grandjean and Bateson, 2021), so the estimated BMDL for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is at the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFDA well.

The BMD_½ SD_ estimate from the multi-PFAS models is threefold higher than the BMD_½ SD_ estimate from the model with just PFDA, and the BMDL_½ SD_ 35% higher. This may or may not reflect control for any potential confounding of the regression effect estimates. While which PFAS model provided the “better" estimate of the point estimate of the effect of PFDA is not clear, the two BMDL_½ SD_ estimates that serve as the PODs are comparable (0.407 ng/mL vs. 0.550 ng/mL), and EPA advanced the POD on the basis of results that did not control for PFOS and PFOA because this model appeared to fit PFDA better (p = 0.11 vs. 0.64) and there was low uncertainty due to potential confounding in the BMDL. However, confidence was diminished by the nonsignificant fit for PFDA (p = 0.11) and stronger potential confounding in the main effect—even though there was low confounding of the BMDL—and overall confidence in the BMDLs for diphtheria was judged low.

For immunotoxicity related to diphtheria, associated with PFDA measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL_½ SD_ of 0.407 ng/mL in serum.

#### Modeling Results for Decreased Tetanus Antibody Concentrations at 5 Years of Age and Perinatal PFDA

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFDA measured perinatally in maternal serum, against log_2_-transformed antitetanus antibody concentrations measured at the 5-year-old examination controlling for sex, and exact age at the 5-year-old examination, cohort, and interaction terms between cohort and sex and between cohort and age. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes of PFDA were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions fit no better than the piecewise-linear functions Budtz-Jørgensen and Grandjean (2018a). Compared to the linear model, the piecewise-linear model fit no better than the linear model for either the PFDA exposure without adjustment for PFOS and PFOA using a likelihood ratio test (p = 0.81; see Budtz-Jørgensen and Grandjean (2018a) Table 3), or for the model that did adjust for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.84).

Table C-5 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for tetanus in this exposure window. These regression coefficients (β), their standard errors (SE), p-values, and the 90% lower confidence bounds were provided by Budtz-Jørgensen and Grandjean (2018b).

Table C-5 Results of the linear analyses of PFDA measured perinatally in maternal serum and tetanus antibodies measured at age 5 years in a single-PFAS model and in a multi-PFAS model from (Budtz-Jørgensen and Grandjean, 2018b)

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum | SE(β) ng/mL in serum | Slope (β) fit | Lower bound slope (β_LB_) per ng/mL in serum
Perinatal PFDA | Linear | No | −0.343 | 0.462 | p = 0.46 | −1.10
Perinatal PFDA | Linear | Yes | 0.038 | 0.554 | p = 0.95 | −0.874

Interpretation of results in Table C-5:

- PFDA is a nonsignificant predictor in the single-PFAS model (β = −0.34; p = 0.46)
- Effects are completely attenuated when log_2_[PFOS] and log_2_[PFOA] are included in the model (β = 0.038; p = 0.55).
- Nevertheless, these data can be used to estimate a BMDL for completeness and to allow comparisons across PFAS.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a 1-SD change in the distribution of log_2_(tetanus antibody concentrations), and ½-SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(tetanus antibody concentrations) at age 5 years was estimated from two sets of distributional data presented from two different cohorts of 5-year-olds that were pooled in Budtz-Jørgensen and Grandjean (2018a). Grandjean et al. (2012) reported on 587 5-year-olds from the cohort of children born during 1997–2000 and in Grandjean et al. (2017) reported on 349 5-year-olds from the cohort of children born during 2007–2009. The means and SDs were computed separately and then pooled to describe the common SD. The IQR of the tetanus antibody concentrations in the earlier birth cohort at age 5 years in IU/mL was (0.1, 0.51). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −0.97). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of tetanus antibodies in log_2_(IU/mL) is (−0.97 – (−3.32))/1.35 = 1.74 log_2_(IU/mL). The IQR of the tetanus antibody concentrations in the later birth cohort at age 5 years in IU/mL was (0.1, 0.3). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −1.74), and the SD of tetanus antibodies in log_2_(IU/mL) is (−1.74 – (−3.32))/1.35 = 1.17 log_2_(IU/mL). The pooled variance is a weighted sum of the independent SDs, and the pooled SD was estimated as 1.55 log_2_(IU/mL).^1^ To show the impact of the BMR on these results, Table C-6 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table C-6 BMDs and BMDLs for effect of PFDA measured perinatally and antitetanus antibody concentrations at age 5 years

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL in serum); β = −0.343 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −1.103 per ng/mL | BMD (ng/mL in serum); β = 0.038 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −0.874 per ng/mL
½ SD | 2.260 | 0.702 ^a^ | – | 0.886
1 SD | 4.520 | 1.405 | – | 1.773

a Denotes the POD that corresponds to the analyses of PFDA concentrations perinatally and tetanus antibodies at age 5 years; – = values cannot be determined.

The lowest perinatal maternal serum PFDA concentration measured was 0.03 ng/mL, the 5th percentile was 0.1 ng/mL, and the 10th percentile was 0.2 ng/mL (Grandjean, 2021), so the estimated BMDLs for a BMR of ½ SD (BMDL_½ SD_ = 0.702 ng/mL) in the single-PFAS model are well above the 10th percentile of the observed distribution. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFDA well. The BMDL_½ SD_ estimate from the single-PFAS models was 0.702 ng/mL in serum. The BMDL estimates from the multi-PFAS models were about 26% higher than for the single-PFAS model.

Confidence in the BMDLs from the PFDA-only model (0.702 ng/mL in serum) and in the multi-PFAS model (0.886 ng/mL in serum) was judged low. Confidence is diminished by the low quality of the model fit for PFDA in either model compared with the PFDA results from tetanus in the 5-year to 7-year exposure-outcome window of time, and there is some uncertainty regarding potential confounding.

For immunotoxicity related to tetanus associated with PFDA measured perinatally, the POD is based on a BMR of ½ SD and a BMDL_½ SD_ of 0.702 ng/mL in serum. Note this result is based on a poorly fit PFDA regression parameter (β) estimated as −0.343 per ng/mL in serum (90% CI: −1.103, 0.417; p = 0.46) Budtz-Jørgensen and Grandjean (2018b), and thus this POD is identified with low confidence.

For immunotoxicity related to tetanus associated with PFDA exposure measured at age 5 years, the POD estimated for comparison purposes is based on a BMR of ½ SD and a BMDL_½ SD_ of 0.702 ng/mL in serum.

#### Modeling Results for Decreased Diphtheria Antibody Concentrations at 5 Years of Age and Perinatal PFDA

Budtz-Jørgensen and Grandjean (2018a) fit multivariate models of PFDA measured perinatally against log_2_-transformed antidiphtheria antibody concentrations measured at the 5-year-old examination controlling for sex and age. Models were evaluated with additional control for PFOS (as log_2_[PFOS]) and PFOA (as log_2_[PFOA]), and without PFOS and PFOA. Three model shapes were evaluated by Budtz-Jørgensen and Grandjean (2018a) using likelihood ratio tests: a linear model of PFDA, a piecewise-linear model with a knot at the median, and a logarithmic function. The logarithmic functions fit no better than the piecewise-linear functions Budtz-Jørgensen and Grandjean (2018a). There was evidence that the piecewise-linear model fit better than the linear model for the PFDA exposure without adjustment for PFOS and PFOA (p = 0.05; see in Budtz-Jørgensen and Grandjean (2018a), Table 3), but not for the model that adjusted for PFOS and PFOA (log_2_[PFOS] and log_2_[PFOA]) (p = 0.12). Table C-7 summarizes the results from Budtz-Jørgensen and Grandjean (2018a) for diphtheria in this exposure window. These regression coefficients (β) and their standard errors (SE) were computed by EPA from the published BMDs and BMDL on the basis of a BMR of 5% change in diphtheria antibody concentrations in Table 2 of Budtz-Jørgensen and Grandjean (2018a).^2^

Table C-7 Results of the analyses of PFDA measured perinatally in maternal serum and diphtheria antibodies measured at age 5 years in a single-PFAS model and in a multi-PFAS model from (Budtz-Jørgensen and Grandjean, 2018b)

Exposure | Model shape | PFOS and PFOA adjusted | Slope (β) per ng/mL in serum | SE(β) | Slope (β) fit | Lower bound slope (β_LB_) per ng/mL in serum
Perinatal PFDA | Piecewise | No | −3.70 | 2.25 | p = 0.100 | −7.40
Perinatal PFDA | Piecewise | Yes | −2.47 | 0.750 | p = 0.001 | −3.700

Interpretation of results in Table C-7:

- PFDA is a nonsignificant predictor in the single-PFAS model (β = −3.700; p = 0.10).
- Effects of PFDA are attenuated when PFOS and PFOA are in the model (β = −2.467; p = 0.001).
- The point estimate results for PFDA are potentially confounded by PFOS and/or PFOA since there was a 33% change in the effect size for PFDA from −3.700 to −2.467 when controlling for PFOS and PFOA.
  ○ One explanation is that PFOS and/or PFOA were confounders of the PFDA effect and controlling for those coexposures removed confounding.
  ○ Another possibility is that controlling for coexposures like PFOS and PFOA actually induced confounding (Weisskopf et al., 2018; Weisskopf and Webster, 2017).
  - The reasons for the change in main effect size for PFDA are unknown. For this reason, there is uncertainty in knowing which point estimate is the best representation of any effect of PFDA.
- However, the lower bound on the point estimates (β_LB_) for the single-PFAS model for PFDA is 100% lower than the multi-PFAS model effect estimate for PFDA.
  ○ The definition of the RfD, which is based on the β_LB_, includes allowing for an order of magnitude (10-fold or 1, 000%) uncertainty in the estimate and the uncertainty for potential confounding in the BMD from including or excluding PFOS and PFOA here is about 33%, while the uncertainty for potential confounding in the BMDL is about 100%.

#### Selection of the Benchmark Response

Following the technical guidance (U.S. EPA, 2012), EPA derived BMDs and BMDLs associated with a 1-SD change in the distribution of log_2_(tetanus antibody concentrations) as a standard reporting level, and ½-SD change in the distribution of log_2_(tetanus antibody concentrations). The SD of the log_2_(diphtheria antibody concentrations) at age 5 years was estimated from two sets of distributional data presented from two different birth cohorts of 5-year-olds that were pooled in Budtz-Jørgensen and Grandjean (2018a). Grandjean et al. (2012) reported on 587 5-year-olds from the cohort of children born during 1997–2000 and Grandjean et al. (2017) reported on 349 5-year-olds from the cohort of children born during 2007–2009. The means and SDs were computed separately and then pooled to describe the common SD. The IQR of the diphtheria antibody concentrations in the earlier birth cohort at age 5 years in IU/mL was (0.05, 0.4). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−4.32, −1.32). Assuming that these log_2_-transformed values are similar to the normal distribution, the width of the IQR is approximately 1.35 SDs, thus SD = IQR/1.35, and the SD of diphtheria antibodies in log_2_(IU/mL) is (−1.32 – (−4.32))/1.35 = 2.22 log_2_(IU/mL). The IQR of the diphtheria antibody concentrations in the later birth cohort at age 5 years in IU/mL was (0.1, 0.3). Log_2_-tranforming these values provides the IQR in log_2_(IU/mL) as (−3.32, −1.74), and the SD of diphtheria antibodies in log_2_(IU/mL) is (−1.74 – (−3.32))/1.35 = 1.17 log_2_(IU/mL). The pooled variance is a weighted sum of the independent SDs, and the pooled SD was estimated as 1.90 log_2_(IU/mL).^3^ To show the impact of the BMR on these results, Table C-8 presents the BMDs and BMDLs at BMRs of ½ SD and 1 SD.

Table C-8 BMDs and BMDLs for effect of PFDA measured perinatally and antidiphtheria antibody concentrations at age 5 years

| Estimated without control of PFOS and PFOA | | Estimated with control of PFOS and PFOA
BMR | BMD (ng/mL in serum); β = −3.700 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −7.400 per ng/mL | BMD (ng/mL in serum); β = −2.467 per ng/mL | BMDL (ng/mL in serum); β_LB_ = −3.700 per ng/mL
½ SD | 0.257 | 0.128 | 0.385 | 0.257 ^a^
1 SD | 0.514 | 0.257 | 0.770 | 0.514

a Denotes the POD that corresponds to the analyses of PFDA concentrations perinatally and diphtheria antibodies at age 5 years.

The lowest serum PFDA concentration measured perinatally was 0.03 ng/mL, the 5th percentile was 0.1 ng/mL, and the 10th percentile was 0.2 ng/mL (Grandjean and Bateson, 2021), so the estimated BMD for a BMR of ½ SD (BMDL_½ SD_) in the single-PFAS model is well within the observed range. No information was available to judge the fit of the model in the range of the BMDLs, but the BMD and BMDL were both within the range of observed values and the model fit PFDA well.

The BMD_½ SD_ estimate from the multi-PFAS models is 50% higher than the BMD_½ SD_ estimated from the model with just PFDA, and the BMDL_½ SD_ is 100% higher. This may or may not reflect control for any potential confounding of the regression effect estimates. The BMDLs that serve as the PODs are twofold different (0.128 ng/mL vs. 0.257 ng/mL) and EPA advanced the derivation on the basis of results that did control for PFOS and PFOA because this model appeared to fit PFDA well (p = 0.001 vs. 0.10) and there was low uncertainty due to potential confounding in the BMD and moderate uncertainty in the BMDL. Confidence in the BMDLs from PFDA linear model (0.257 ng/mL in serum) with control of PFOS and PFOA is judged medium since the model fit reasonably well and these BMDLs show moderate uncertainty about confounding.

For immunotoxicity related to diphtheria, associated with PFDA measured at age 5 years, the POD is based on a BMR of ½ SD and a BMDL_½ SD_ of 0.257 ng/mL in serum.

#### Summary of Modeling Results for Decreased Antibody Responses in Children

Table C-9 presents the BMDs and BMDLs from Budtz-Jørgensen and Grandjean (2018a) considered for POD derivation for reduced antibody responses across different combinations of exposure timing and outcome measurement, as detailed above. The BMDLs across the studies and methods ranged from 0.257 to 0.702 ng/mL.

Table C-9 Selected BMDs and BMDLs and associated uncertainty for effect of PFDA on decreased antibody responses in children from Budtz-Jørgensen and Grandjean (2018a)

Endpoint | BMD_1/2SD_ (ng/mL) | BMDL_1/2SD_ (ng/mL) | Confidence
Decreased serum tetanus antibody concentrations at 7 yr of age and PFDA measured at 5 yr of age^a^ | 0.673 | 0.411 | Medium
Decreased serum diphtheria antibody concentrations at 7 yr of age and PFDA concentrations at 5 yr of age^a^ | 0.827 | 0.407 | Low
Decreased serum tetanus antibody concentrations at 5 yr of age and perinatal PFDA (pregnancy wk 32–2 wk postpartum)^a^ | 2.260 | 0.702 | Low
Decreased serum diphtheria antibody concentrations at 5 yr of age and perinatal PFDA (pregnancy wk 32–2 wk postpartum)^b^ | 0.385 | 0.257 | Medium

a Estimated without control for PFOS and PFOA.

b Estimated with control for PFOS and PFOA.

### C.1.2 Benchmark Dose Modeling Approaches for Developmental Effects

#### Modeling Results for Decreased Birth Weight

Five high confidence studies (Luo et al., 2021; Yao et al., 2021; Wikström et al., 2020; Valvi et al., 2017; Division of Environmental Epidemiology et al., 2016) reported decreased birth weight in infants whose mothers were exposed to PFDA. All studies reported exposure metrics in units of ng/mL and reported the β coefficients per ln(ng/mL) or per log_2_(ng/mL), along with 95% confidence intervals, estimated from linear regression models. The logarithmic transformation of exposure yields a negative value for low numbers, which can result in implausible results from dose-response modeling (i.e., estimated risks are negative and responses at zero exposure cannot be determined). EPA first re-expressed the reported β coefficients in terms of per ng/mL according to Dzierlenga et al. (2020). Then EPA used the re-expressed β and the lower limit on the confidence interval to estimate BMD and BMDL values using the general equation y = mx + b, where y is birth weight and x is exposure, substituting the re-expressed β values from these studies for m. The intercept b represents the baseline value of birth weight in an unexposed population, and it can be estimated through y‾ = m x‾ + b using an average birth weight from an external population as y‾ , an average exposure as x‾ , and a re-expressed β from the studies as m.

The CDC Wonder site (https://wonder.cdc.gov/natality.html) provides vital statistics for babies born in the United States. There were 3, 791, 712 live births in the United States in 2018 according to final natality data. The mean and standard deviation for birth weight were 3, 261.6 ± 590.7 g (7.19 ± 1.30 lb), with 8.27% of live births falling below the public health definition of low birth weight (i.e., <2,500 g, or 5.5 lb). The full natality data for the U.S. data on birth weight was used as it is more relevant for deriving toxicity values for the U.S. public than the study-specific birthweight data. Also, the CDC Wonder database may be queried to find the exact percentage of the population falling below the cutoff value for clinical adversity. The CDC National Health and Nutrition Examination Survey (NHANES) Biomonitoring Data for Environmental Chemicals (https://www.cdc.gov/exposurereport/data_tables.html) provides the median serum PFDA concentrations (0.19 ng/mL) among NHANES females in 2011–2012. These values are subsequently used in the estimation of BMD and BMDL values from the available five epidemiological studies.

Valvi et al. (2017) reported a β coefficient of −41 g per log_2_(ng/mL) (95% CI: −102,18) for the association between birth weight and maternal PFDA serum concentrations in a Denmark cohort. The reported β coefficient can be re-expressed in terms of per ng/mL according to (Dzierlenga et al., 2020). Given the reported study-specific median (0.28 ng/mL) and interquartile range (IQR) (0.22–0.38 ng/mL) of the exposure from (Valvi et al., 2017), EPA estimated the distribution of exposure by assuming the exposure follows a log-normal distribution with mean and standard deviation as:

μ = l n (q_50_) = l n ( 0.28 ) = - 1.27 C-1

σ = l n (q_75_ / q_25_) / 1.349 = l n ( 0.38 / 0.22 ) / 1.349 = 0.41 C-2

Then, EPA estimated the 25th–75th percentiles at 10 percentile intervals of the exposure distribution and corresponding responses of reported β coefficient. The re-expressed β coefficient is determined by minimizing the sum of squared differences between the curves generated by the re-expressed β and the reported β. This resulted in a re-expressed β coefficient of −207.7 g per ng/mL (95% CI: −516.8, 91.2 g per ng/mL).

Typically, for continuous data, the preferred definition of the benchmark response (BMR) is to have a basis for what constitutes a minimal level of change in the endpoint that is biologically significant. For birth weight, there is no accepted percentage change that is considered adverse. However, there is a clinical measure for what constitutes an adverse response: babies born weighing less than 2,500 g are considered to have low birth weight, and further, low birth weight is associated with a wide range of health conditions throughout life (Tian et al., 2019; Reyes and Mañalich, 2005; Hack et al., 1995). Given this clinical cutoff for adversity and that 8.27% of live births in the United States in 2018 fell below this cutoff, the hybrid approach can be used to define the BMR. The hybrid approach is advantageous in that it harmonizes the definition of the BMR for continuous data with that for dichotomous data.^4^ Essentially, the hybrid approach involves the estimation of the dose that increases the percentile of responses falling below (or above) some cutoff for adversity in the tail of the response distribution. Application of the hybrid approach requires the selection of an extra risk value for BMD estimation. In the case of birth weight, an extra risk of 5% is selected given that this level of response is typically used when modeling developmental responses from animal toxicology studies, and that low birthweight confers increased risk for adverse health effects throughout life, thus supporting a BMR lower than the standard BMR of 10% extra risk.

Therefore, given a background response and a BMR = 5% extra risk, the BMD would be the dose that results in 12.86% of the responses falling below the 2,500 g cutoff value:

Extra Risk ( E R ) = ( P ( d ) - P ( 0 ) ) / ( 1 - P ( 0 ) ) C-3

P ( d ) = E R ( 1 - P ( 0 ) ) + P ( 0 ) = 0.05 ( 1 - 0.0827 ) + 0.0827 = 0.1286 C-4

On the basis of the mean birth weight for all births in the United States of 3, 261.6 g with a standard deviation of 590.7 g, EPA calculated the mean response that would be associated with the 12.86th percentile of the distribution falling below 2,500 g. In this case, the mean birth weight would be 3, 169.2 g. Given the median exposure among NHANES females as x‾ , the mean birth weight in the United States as y‾ , and the re-expressed β as m term, the intercept b can be estimated as:

b = y‾ - m x‾ = 3, 261.6 g - (- 207.7 g ( (n g)/(m L) )^- 1^) 0.19 (n g)/(m L) = 3, 301.1 g C-5

The BMD was calculated by rearranging the equation y = mx + b and solving for x, using 3, 301.1 g for the b term and −207.7 for the m term. This resulted in a value of 0.63 ng/mL:

x = ( y - b ) / m = ( 3, 169.2 g - 3, 301.1 g ) / ( - 207.7 g ( (n g)/(m L) )^- 1^ ) = 0.63 n g / m L C-6

To calculate the BMDL, the method is essentially the same except that the lower limit on the re-expressed β coefficient (−516.8 g per ng/mL) is used for the m term. However, (Valvi et al., 2017) reports a two-sided 95% confidence interval for the β coefficient, meaning that the lower limit of that confidence interval corresponds to a 97.5% one-sided lower limit. The BMDL is defined as the 95% lower limit of the BMD (i.e., corresponds to a two-sided 90% confidence interval), so the corresponding lower limit on the re-expressed β coefficient needs to be calculated before calculating the BMDL. First, the standard error of the re-expressed β coefficient can be calculated as:

S E = (Upper Limit-Lower Limit)/(3.92) = (91.2 g ( (n g)/(m L) )^- 1^ - ( - 516.8 g ( (n g)/(m L) )^- 1^ ))/(3.92) = 155.1 g ( (n g)/(m L) )^- 1^ C-7

Then the corresponding 95% one-sided lower limit on the re-expressed β coefficient is calculated as:

95 % one - sided L L = β - 1.645 ( S E ( β ) ) = - 207.7 g ( (n g)/(m L) )^- 1^ - 1.645 ( 155.1 g ( (n g)/(m L) )^- 1^ ) = - 462.9 g ( (n g)/(m L) )^- 1^ C-8

Using this value for the m term results in a BMDL value of 0.28 ng/mL maternal serum concentration.

Valvi et al. (2017) also reported a β coefficient of −44 g per log_2_(ng/mL) (95% CI: −133, 44 g per log_2_(ng/mL) for boys and −28 g per log_2_(ng/mL) (95% CI: −110, 54 g per log_2_(ng/mL)) for girls. The re-expressed β coefficients are −222.9 g per ng/mL (95% CI: −673.9, 222.9 g per ng/mL) and −141.9 g per ng/mL (95% CI: −557.3, 273.6 g per ng/mL), and the intercepts b are 3, 304.0 g and 3, 288.6 g for boys and girls, respectively. Using these sex-specific values, the estimated BMD values are 0.60 ng/mL for boys and 0.84 ng/mL for girls.

To calculate the BMDL, the same procedure as above is used to calculate the corresponding 95% one-sided lower limit for the re-expressed β coefficient from the re-expressed lower limit on the 95% two-sided confidence interval of −673.9 g per ng/mL for boys and −557.3 g per ng/mL for girls. Using the corresponding lower limit (−599.2 g per ng/mL for boys and −490.5 g per ng/mL for girls), the BMDLs of 0.22 ng/mL for boys and 0.24 ng/mL for girls are calculated.

Division of Environmental Epidemiology et al. (2016) reported a β coefficient of −43.9 g per ln(ng/mL) (95% CI: −104.8, 17.0 g per ln(ng/mL) for the association between birth weight and maternal PFDA serum concentrations in a multicountry cohort. Given the reported study-specific geometric mean (0.25) and standard deviation of ln-transformed exposure (0.70), EPA estimated the mean (−1.41) and standard deviation (0.70) of the log normally distributed exposure. The re-expressed β coefficient is −122.2 g (95% CI: −291.5, 47.2) per ng/mL, and the intercept b is 3, 284.8 g. The 95% one-sided lower limits for the re-expressed β coefficient are −264.3 g per ng/mL. The values of the BMD and BMDL are 0.95 ng/mL and 0.44 ng/mL, respectively.

Luo et al. (2021) reported a β coefficient of −96.8 g per ln(ng/mL) (95% CI: −178.0, −15.5 g per ln(ng/mL)) for the association between birth weight and maternal PFDA serum concentrations in a China cohort. Given the reported study-specific median (0.48 ng/mL) and IQR (0.34–0.70 ng/mL) of the exposure, EPA estimated the mean (−0.73) and standard deviation (0.54) of the log normally distributed exposure. The re-expressed β coefficient is −195.8 g per ng/mL (95% CI: −360.2, −31.4 g per ng/mL), and the intercept b is 3, 298.8 g. The 95% one-sided lower limits for the re-expressed β coefficient are −333.8 g per ng/mL. The values of the BMD and BMDL are 0.66 ng/mL and 0.39 ng/mL, respectively.

Wikström et al. (2020) reported a β coefficient of −58.0 g per ln(ng/mL) (95% CI: −103.0, −13.0 g per ln(ng/mL)) for the association between birth weight and maternal PFDA serum concentrations in a Swedish cohort. Given the reported study-specific median (0.26 ng/mL) and IQR (0.19–0.34 ng/mL) of the exposure, EPA estimated the mean (−1.35) and standard deviation (0.43) of the log normally distributed exposure. The re-expressed β coefficient is −218.9 g per ng/mL (95% CI: −388.7, −49.1 g per ng/mL) and the intercept b is 3, 303.2 g. The 95% one-sided lower limits for the re-expressed β coefficient are −361.4 g per ng/mL. The values of the BMD and BMDL are 0.61 ng/mL and 0.37 ng/mL, respectively.

Wikström et al. (2020) also reported β coefficients of −47 g per ln(ng/mL) (95% CI: −112,17 g per ln(ng/mL)) for boys and −69 g per ln(ng/mL) (95% CI: −133, −6 g per ln(ng/mL)) for girls. The re-expressed β coefficients are −177.4 g per (95% CI: −422.7, 64.2 g per ng/mL) and −260.4 g per (95% CI: −501.9, −22.6 g per ng/mL), and the intercepts b are 3, 295.3 g and 3, 311.1 g for boys and girls, respectively. Using these sex-specific values, the estimated BMD values are 0.71 ng/mL for boys and 0.54 ng/mL for girls. The corresponding 95% one-sided lower limits for the re-expressed β coefficient are −381.6 g per and −461.5 g per for boys and girls, respectively. The BMDL values are 0.33 ng/mL for boys and 0.31 ng/mL for girls.

Yao et al. (2021) reported a β coefficient of −46.3 g per ln(ng/mL) (95% CI: −131.1, 38.5 g per ln(ng/mL)) for the association between birth weight and maternal PFDA serum concentrations in a China cohort. Given the reported study-specific median (0.55 ng/mL) and IQR (0.37–0.74 ng/mL) of the exposure, EPA estimated the mean (−0.60) and standard deviation (0.51) of the log normally distributed exposure. The re-expressed β coefficient is −82.0 g per (95% CI: −232.1, 68.1 g per ng/mL) and the intercept b is 3, 277.2 g. The 95% one-sided lower limits for the re-expressed β coefficient are −208.0 g per ng/mL. The values of the BMD and BMDL are 1.32 ng/mL and 0.52 ng/mL, respectively.

For all the above calculations, EPA used the exact percentage (8.27%) of live births in the United States in 2018 that fell below the cutoff of 2, 500 g as the tail probability to represent the probability of extreme ("adverse") response at zero dose (P(0)). However, this exact percentage of 8.27% was calculated without accounting for the existence of background PFDA exposure in the U.S. population (i.e., 8.27% is not the tail probability of extreme response at zero dose). Thus, EPA considers an alternative control-group response distribution (N(μ_c_, σ_c_)), using the study-specific intercept b obtained through equation (C-5) (representing the baseline value of birth weight in an unexposed population) as μ_c_ and the standard deviation of the U.S. population as σ_c_, to estimate the tail probability that fell below the cutoff of 2, 500 g. EPA estimated the study-specific tail probability of live births falling below the public health definition of low birth weight (2, 500 g) as:

P ( 0 ) = (1)/(σ_c_ sqrt(2 π)) ∫_- ∞_^2500^ e^( - (( x - b )^2^)/(2 σ_c_^2^) )^ d x = (1)/(590.7 sqrt(2 π)) ∫_- ∞_^2500^ e^( - (( x - b )^2^)/(2 * 590 . 7^2^) )^ d x C-9

b = y‾ - m x‾ = 3, 261.6 - (β_r e - expressed_ * 0.19 (n g)/(m L)) C-10

In this alternative approach, P(0) is 9.86% if there is no background exposure x‾ = 0 . By using the median serum PFDA concentrations (0.19 ng/mL) from NHANES females in 2011–2012 as background exposure ( x‾ ) , the tail probabilities using this alternative approach were study specific and ranged from 8.48% to 9.41%. As such, the results from this alternative approach, presented under the column of “Alternative Tail Probability" in Table C-10, are very similar to the main results, presented under the column of “Exact Percentage” in Table C-10, when background exposure was not accounted for when estimating the tail probability.

The SAS code and results are provided by (Ru and Davis, 2024). Table C-10 presents the BMDs and BMDLs for all studies considered for POD derivation, with and without accounting for background exposure when estimating the percentage of the population falling below the cutoff value from (Ru and Davis, 2024). The BMDLs across the studies and methods ranged from 0.22 ng/mL to 0.66 ng/mL.

Table C-10 BMDs and BMDLs for effect of PFDA on decreased birth weight, using percentage (8.27%) of live births falling below the public health definition of low birth weight, or alternative study-specific tail probability

Study | Exposure median (IQR) or GM (SD) | Exposure distribution (μ, σ) | Reported β (95% CI) | Re-expressed β (95% CI) g/ng/mL | Intercept b | SE of β | 95% one-sided LL of β | Exact percentage (p(0) = (0) = 8.27%) | | Alternative tail probability
Study | Exposure median (IQR) or GM (SD) | Exposure distribution (μ, σ) | Reported β (95% CI) | Re-expressed β (95% CI) g/ng/mL | Intercept b | SE of β | 95% one-sided LL of β | BMD (ng/mL) | BMDL (ng/mL) | P(0) | BMD (ng/mL) | BMDL (ng/mL)
Valvi et al. (2017) | 0.28 (0.22–0.38) | (−1.27, 0.41) | −41.0 (−102.0, 18.0) g/log_2_(ng/mL) | −207.7 (−516.8, 91.2) | 3, 301.1 | 155.11 | −462.9 | 0.63 | 0.28 | 8.75% | 0.70 | 0.31
Valvi et al. (2017) Boys | 0.28 (0.22–0.38) | (−1.27, 0.41) | −44.0 (−133.0, 44.0) g/log_2_(ng/mL) | −222.9 (−673.9, 222.9) | 3, 304.0 | 228.78 | −599.2 | 0.60 | 0.22^b^ | 8.67% | 0.65 | 0.24
Valvi et al. (2017) Girls | 0.28 (0.22–0.38) | (−1.27, 0.41) | −28.0 (−110.0, 54.0) g/log_2_(ng/mL) | −141.9 (−557.3, 273.6) | 3, 288.6 | 211.98 | −490.5 | 0.84 | 0.24 | 9.09% | 0.99 | 0.29
Division of Environmental Epidemiology et al. (2016) | 0.25 (0.70)^c^ | (−1.41, 0.70) | −43.9 (−104.8, 17.0) g/ln(ng/mL) | −122.2 (−291.5, 47.2) | 3, 284.8 | 86.40 | −264.3 | 0.95 | 0.44 | 9.20% | 1.14 | 0.53
Luo et al. (2021) | 0.48 (0.34–0.70) | (−0.73, 0.54) | −96.8 (−178.0, −15.5) g/ln(ng/mL) | −195.8 (−360.2, −31.4) | 3, 298.8 | 83.88 | −333.8 | 0.66 | 0.39 | 8.81% | 0.73 | 0.43
Wikström et al. (2020) | 0.26 (0.19–0.34) | (−1.35, 0.43) | −58.0 (−103.0, −13.0) g/ln(ng/mL) | −218.9 (−388.7, −49.1) | 3, 303.2 | 86.64 | −361.4 | 0.61 | 0.37 | 8.69% | 0.66 | 0.40
Wikström et al. (2020) Boys | 0.26 (0.19–0.34) | (−1.35, 0.43) | −47.0 (−112.0, 17.0) g/ln(ng/mL) | −177.4 (−422.7, 64.2) | 3, 295.3 | 124.19 | −381.6 | 0.71 | 0.33 | 8.91% | 0.80 | 0.37
Wikström et al. (2020) Girls | 0.26 (0.19–0.34) | (−1.35, 0.43) | −69.0 (−133.0, −6.0) g/ln(ng/mL) | −260.4 (−501.9, −22.6) | 3, 311.1 | 122.26 | −461.5 | 0.54 | 0.31 | 8.48% | 0.57 | 0.32
Yao et al. (2021) | 0.55 (0.37–0.74) | (−0.60, 0.51) | −46.3 (−131.1, 38.5) g/ln(ng/mL) | −82.0 (−232.1, 68.1) | 3, 277.2 | 76.58 | −208.0 | 1.32 | 0.52 | 9.41% | 1.68 | 0.66

a The alternative study-specific tail probability of live births falling below the public health definition of low birth weight is based on a normal distribution with intercept b as the mean and a standard deviation of 590.7 based on the U.S. population.

b Smallest BMDL using the five individual studies.

c Division of Environmental Epidemiology et al. (2016) reports Geometric Mean (GM) and standard deviation (SD) of ln-transformed concentrations.

## C.2 BENCHMARK DOSE MODELING RESULTS FROM ANIMAL STUDIES

### C.2.1 Benchmark Dose Modeling Approaches

The endpoints selected for benchmark dose (BMD) modeling are listed in Table C-11. The animal doses in the study were used in the BMD modeling and then converted to human equivalent doses (HEDs) using data-derived extrapolation factors (DDEFs) described in Section 3.1.7 of the main document; the modeling results are presented in this appendix and (Ru and Davis, 2024).

#### Modeling Procedure for Dichotomous Noncancer Data

BMD modeling of dichotomous noncancer data was conducted using EPA's Benchmark Dose Software (BMDS, version 3.2). For these data, the Gamma, Logistic, Log-Logistic, Log-Probit, Multistage, Probit, Weibull, and Dichotomous Hill models available within the software were fit using a benchmark response (BMR) of 10% extra risk (see Toxicological Review, Section 5.2.1 for justification of selected BMRs). The Multistage model is run for all polynomial degrees up to n - 2, where n is the number of dose groups including control. Adequacy of model fit was judged on the basis of χ^2^ goodness-of-fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined benchmark response (absolute value < 2.0), and visual inspection of the model fit. In the cases for which no best model was found to fit to the data, a reduced dataset without the high-dose group was used for modeling and the result presented with that of the full dataset. In cases for which a model with several parameters equal to the number of dose groups was fit to the dataset, all parameters were estimated, and no p-value was calculated, that model was not considered for estimating a point of departure (POD) unless no other model provided adequate fit. Among all models providing adequate fit, the benchmark dose lower confidence limit (BMDL) from the model with the lowest Akaike's information criterion (AIC) was selected as a potential POD when BMDL values were sufficiently close (within threefold). Otherwise, the lowest BMDL was selected as a potential POD.

#### Modeling Procedure for Continuous Noncancer Data

BMD modeling of continuous noncancer data was conducted using EPA's Benchmark Dose Software (BMDS, version 3.2). For these data, the Exponential, Hill, Polynomial, and Power models available within the software are fit using a BMR of 1 standard deviation (SD) when no toxicological information was available to determine an adverse level of response. When toxicological information was available, the BMR was based on relative deviation, as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2012) (see Toxicological Review, Section 5.2.1 justification for using BMRs); when a BMR based on relative deviation was used, modeling results using BMRs based on SD are included for reference. An adequate fit is judged on the basis of χ^2^ goodness-of-fit p-value (p > 0.1), scaled residuals at the data point (except the control) closest to the predefined benchmark response (absolute value <2.0), and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made on whether the variance across dose groups is homogeneous. If a homogeneous variance model is deemed appropriate on the basis of the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. If the test for homogeneity of variance is rejected (p < 0.05), the model is run again while modeling the variance as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.05), alternative approaches are assessed on a case-by-case basis. For example, in cases for which neither variance model fit, or constant variance did not fit (with adequate Test-4 p-value) and nonconstant variance did fit (with inadequate Test-4 p-value), the log-normal distribution was attempted.

In cases for which a model with several parameters equal to the number of dose groups was fit to the dataset, all parameters were estimated, and no p-value was calculated, that model was not considered for estimating a POD unless no other model provided adequate fit. Among all models providing adequate fit, the BMDL from the model with the lowest AIC was selected as a potential POD when BMDL estimates differed by less than threefold. When BMDL estimates differed by greater than threefold, the model with the lowest BMDL was selected to account for model uncertainty.

#### Modeling Procedure for Continuous Noncancer Developmental Toxicity Data

For continuous developmental toxicity data, data for individual animals were requested from the study authors when possible. The use of individual animal data allows for the correct measure of variance to be calculated. When a biological rationale for selecting a benchmark response level is lacking, a BMR equal to 0.5 SD was used. The use of 1 SD for the BMR for continuous endpoints is based on the observation that shifting the distribution of the control group by 1 SD results in ∼10% of the animal data points falling beyond an adversity cutoff defined at the ∼1.5 percentile (Crump, 1995). This approximates the 10% extra risk commonly used as the BMR for dichotomous endpoints. Thus, the use of 0.5 SD for continuous developmental toxicity endpoints approximates the extra risk commonly used for dichotomous developmental toxicity endpoints.

#### Data Used for Modeling

The source of the data used for modeling endpoints from animal studies is provided in Table C-11. These data also are included in full in the tables below.

Table C-11 Sources of data used in benchmark dose modeling of PFDA endpoints from animal studies

Endpoint/Reference | Reference | HAWC link
↑ AST – M | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506861/
↑ AST – F | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506957/
↑ ALP – F | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506956/
↑ Relative liver weight – M | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506814/
↑ Relative liver weight – F | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506920/
↑ Relative liver weight – F (Histopathology cohort) | Frawley et al. (2018) | https://hawcprd.epa.gov/ani/endpoint/100506676/
↑ Relative liver weight – F (MPS cohort) | Frawley et al. (2018) | https://hawcprd.epa.gov/ani/endpoint/100506669/
↑ Relative liver weight – F (TDAR to SRBC cohort) | Frawley et al. (2018) | https://hawcprd.epa.gov/ani/endpoint/100506677/
↓ Fetal body weight (GD 6–15) | Harris and Birnbaum (1989) | https://hawcprd.epa.gov/ani/endpoint/100506643/
↓ Caudal epididymis sperm count | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506879/
↓ Absolute testis weight | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506820/
↓ Absolute cauda epididymis weight | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506878/
↓ Absolute whole epididymis weight | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506877/
↓ Estrus time | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100524936/
↑ Diestrus time | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100524930/
↓ Relative uterus weight | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506941/
↓ Absolute uterus weight | NTP (2018) | https://hawcprd.epa.gov/ani/endpoint/100506940/

### C.2.2 Increased AST – Male Rats (NTP, 2018)^5^

Table C-12 Dose-response data for increased AST in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 65.3 | 10.18
0.156 | 10 | 74 | 9.55
0.312 | 10 | 77.3 | 16.98
0.625 | 10 | 81.3 | 9.84
1.25 | 10 | 87.5 | 14.61
2.5 | 9 | 92.67 | 8.04

Table C-13 Benchmark dose results for increased AST in male rats – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.3924 | 1.0640 | 0.1386 | 467.4755 | Viable – Alternate
Exponential 3 (CV – normal) | Restricted | 1.3924 | 1.0640 | 0.1386 | 467.4755 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.3933 | 0.1723 | 0.8692 | 463.2441 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.3949 | 0.1723 | 0.8692 | 463.2441 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.3266 | 0.1227 | 0.9560 | 462.8481 | Viable – Recommended | Lowest BMDL
Polynomial (5 degree) (CV – normal) | Restricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate
Polynomial (4 degree) (CV – normal) | Restricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate
Polynomial (3 degree) (CV – normal) | Restricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate
Power (CV – normal) | Restricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 1.2558 | 0.9260 | 0.1910 | 466.6376 | Viable – Alternate

Figure C-3 Dose-response curve for the Hill model fit to increased AST in male rats (NTP, 2018).

Figure C-3. Dose-response curve for the Hill model fit to increased AST in male rats (NTP, 2018).

Figure C-4 User Input for dose-response modeling of increased AST in male rats (NTP, 2018).

Figure C-4. User Input for dose-response modeling of increased AST in male rats (NTP, 2018).

Figure C-5 Model Results for increased AST in male rats (NTP, 2018).

Figure C-5. Model Results for increased AST in male rats (NTP, 2018).

### C.2.3 Increased AST – Female Rats (NTP, 2018)

Table C-14 Dose-response data for increased AST in female rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 62.6 | 10.75
0.156 | 9 | 60.44 | 6.51
0.312 | 10 | 57.9 | 4.11
0.625 | 10 | 63.3 | 5
1.25 | 10 | 81.9 | 8.29
2.5 | 7 | 112.57 | 22.54

Table C-15 Benchmark dose results for increased AST in female rats – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.6219 | 0.5312 | 0.1426 | 427.8867 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 3 (CV – normal) | Restricted | 0.8024 | 0.5551 | 0.1375 | 428.5314 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 4 (CV – normal) | Restricted | 0.5006 | 0.0000 | 0.0153 | 433.4316 | Unusable | BMD computation failed; lower limit includes zero; BMDL not estimated; Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 5 (CV – normal) | Restricted | 0.1055 | 0.1048 | <0.0001 | 553.6193 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Hill (CV – normal) | Restricted | 0.9445 | 0.6992 | 0.5341 | 426.2660 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (5 degree) (CV – normal) | Restricted | 0.8055 | 0.5285 | 0.1331 | 428.6052 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (4 degree) (CV – normal) | Restricted | 0.8055 | 0.5285 | 0.1331 | 428.6052 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Constant variance
Polynomial (3 degree) (CV – normal) | Restricted | 0.8055 | 0.5285 | 0.1331 | 428.6052 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (2 degree) (CV – normal) | Restricted | 0.8055 | 0.5285 | 0.1331 | 428.6052 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Power (CV – normal) | Restricted | 0.8126 | 0.5686 | 0.2122 | 427.5127 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Linear (CV – normal) | Unrestricted | 0.5006 | 0.4134 | 0.0339 | 431.4316 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Table C-16 Benchmark dose results for increased AST in female rats – nonconstant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 0.4683 | 0.3822 | 0.0006 | 417.7886 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (NCV – normal) | Restricted | 0.7433 | 0.5327 | 0.0048 | 413.2499 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 4 (NCV – normal) | Restricted | 0.4044 | 0.3201 | <0.0001 | 425.5227 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 5 (NCV – normal) | Restricted | 0.9173 | 0.6965 | 0.0484 | 408.4035 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Hill (NCV – normal) | Restricted | 1.1570 | 0.6738 | 0.0375 | 408.9143 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Nonconstant variance
Polynomial (5 degree) (NCV – normal) | Restricted | 0.8488 | 0.5738 | 0.0172 | 410.3710 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (4 degree) (NCV – normal) | Restricted | 0.8488 | 0.5738 | 0.0172 | 410.3710 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (3 degree) (NCV – normal) | Restricted | 0.8488 | 0.5738 | 0.0172 | 410.3710 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (2 degree) (NCV – normal) | Restricted | 0.8488 | 0.5738 | 0.0172 | 410.3710 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Power (NCV – normal) | Restricted | 0.7553 | 0.5621 | 0.0104 | 411.6066 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Linear (NCV – normal) | Unrestricted | 0.4052 | 0.3203 | <0.0001 | 423.4964 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Table C-17 Benchmark dose results for increased AST in female rats – log-normal, constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – log-normal) | Restricted | 0.4981 | 0.4114 | 0.0353 | 410.1569 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 3 (CV – log-normal) | Restricted | 0.7017 | 0.4707 | 0.0518 | 409.5663 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Constant variance
Exponential 4 (CV – log-normal) | Restricted | 0.4173 | 0.0000 | 0.0061 | 414.2361 | Unusable | BMD computation failed; lower limit includes zero; BMDL not estimated; Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 5 (CV – log-normal) | Restricted | −9, 999.0000 | 0.0000 | <0.0001 | 482.3726 | Unusable | BMD computation failed; lower limit includes zero BMD not estimated; BMDL not estimated; Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Hill (CV – log-normal) | Restricted | 0.8526 | 0.6413 | 0.4051 | 405.6388 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); \|Residual at control\| > 2
Polynomial (5 degree) (CV – log-normal) | Restricted | 0.7220 | 0.4645 | 0.0501 | 409.6412 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (4 degree) (CV – log-normal) | Restricted | 0.7220 | 0.4645 | 0.0501 | 409.6412 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (3 degree) (CV – log-normal) | Restricted | 0.7220 | 0.4645 | 0.0501 | 409.6412 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (2 degree) (CV – log-normal) | Restricted | 0.7220 | 0.4645 | 0.0501 | 409.6412 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Constant variance
Power (CV – log-normal) | Restricted | 0.7158 | 0.5034 | 0.0953 | 408.1933 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Linear (CV – log-normal) | Unrestricted | 0.4170 | 0.3303 | 0.0061 | 414.2360 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2

### C.2.4 Increased ALP – Female Rat (NTP, 2018)

Table C-18 Dose-response data for increased ALP in female rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 9 | 136.4 | 18.6
0.156 | 9 | 156.1 | 24
0.312 | 10 | 182.8 | 36.68
0.625 | 10 | 184.2 | 33.2
1.25 | 10 | 281.1 | 72.42
2.5 | 7 | 262.4 | 60.06

Table C-19 Benchmark dose results for increased ALP in female rats— BMR = constant variance, 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.2058 | 0.9747 | <0.0001 | 598.0449 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 3 (CV – normal) | Restricted | 1.2058 | 0.9747 | <0.0001 | 598.0449 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 4 (CV – normal) | Restricted | 0.3043 | 0.1894 | 0.0206 | 585.6900 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 5 (CV – normal) | Restricted | 0.6977 | 0.3389 | 0.0530 | 583.7962 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Hill (CV – normal) | Restricted | 0.6547 | 0.6162 | 0.1011 | 582.1450 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (5 degree) (CV – normal) | Restricted | 0.9018 | 0.6940 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (4 degree) (CV – normal) | Restricted | 0.9018 | 0.6940 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (3 degree) (CV – normal) | Restricted | 0.9018 | 0.6940 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (2 degree) (CV – normal) | Restricted | 0.9018 | 0.6940 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Power (CV – normal) | Restricted | 0.9018 | 0.6941 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Linear (CV – normal) | Unrestricted | 0.9018 | 0.6940 | 0.0005 | 594.1122 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.

Table C-20 Benchmark dose results for increased ALP in female rats— nonconstant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 0.3761 | 0.2620 | <0.0001 | 578.1584 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 3 (NCV – normal) | Restricted | 0.3761 | 0.2620 | <0.0001 | 578.1584 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 4 (NCV – normal) | Restricted | 0.1191 | 0.0720 | 0.0174 | 565.0835 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 5 (NCV – normal) | Restricted | 0.1556 | 0.0758 | 0.0083 | 566.5363 | Questionable | Goodness-of-fit p-value < 0.1
Hill (NCV – normal) | Restricted | 0.1501 | 0.0700 | 0.0056 | 567.3018 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (5 degree) (NCV – normal) | Restricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (4 degree) (NCV – normal) | Restricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (3 degree) (NCV – normal) | Restricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (2 degree) (NCV – normal) | Restricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1
Power (NCV – normal) | Restricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1
Linear (NCV – normal) | Unrestricted | 0.2457 | 0.1655 | 0.0012 | 570.9484 | Questionable | Goodness-of-fit p-value < 0.1

Table C-21 Benchmark dose results for increased ALP in female rats—log-normal, constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – log-normal) | Restricted | 0.8447 | 0.6570 | 0.0001 | 575.0495 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 3 (CV – log-normal) | Restricted | 0.8447 | 0.6570 | 0.0001 | 575.0495 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 4 (CV – log-normal) | Restricted | 0.2215 | 0.1355 | 0.0337 | 563.1028 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 5 (CV – log-normal) | Restricted | 0.3331 | 0.1470 | 0.0200 | 564.2382 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Hill (CV – log-normal) | Restricted | 0.2860 | 0.1283 | 0.0121 | 565.2461 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (5 degree) (CV – log-normal) | Restricted | 0.5606 | 0.4106 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (4 degree) (CV – log-normal) | Restricted | 0.5606 | 0.4106 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (3 degree) (CV – log-normal) | Restricted | 0.5606 | 0.4106 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (2 degree) (CV – log-normal) | Restricted | 0.5606 | 0.4106 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Power (CV – log-normal) | Restricted | 0.5606 | 0.4107 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Linear (CV – log-normal) | Unrestricted | 0.5606 | 0.4106 | 0.0017 | 569.7238 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2

### C.2.5 Increased Relative Liver Weight – Male Rat (NTP, 2018)

Table C-22 Dose-response data for increased relative liver weight in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 35.5 | 3.07
0.156 | 10 | 39.32 | 1.68
0.312 | 10 | 42.61 | 1.77
0.625 | 10 | 45.56 | 2.66
1.25 | 10 | 54.77 | 2.15
2.5 | 10 | 67.9 | 3.76

Table C-23 Benchmark dose results for increased relative liver weight in male rats—constant variance, BMR = 10% relative deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.4081 | 0.3852 | <0.0001 | 314.8501 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (CV – normal) | Restricted | 0.4081 | 0.3852 | <0.0001 | 314.8501 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (CV – normal) | Restricted | 0.2116 | 0.1764 | 0.2654 | 291.5391 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.2112 | 0.1764 | 0.2653 | 291.5398 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.2078 | 0.1710 | 0.2774 | 291.4313 | Viable Recommended | Lowest AIC
Polynomial (5 degree) (CV – normal) | Restricted | 0.2978 | 0.2836 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (CV – normal) | Restricted | 0.2978 | 0.2778 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (CV – normal) | Restricted | 0.2978 | 0.2775 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (CV – normal) | Restricted | 0.2978 | 0.2775 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (CV – normal) | Restricted | 0.2978 | 0.2775 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (CV – normal) | Unrestricted | 0.2978 | 0.2775 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Figure C-6 Dose-response curve for the Hill model fit to increased relative liver weight in male rats (NTP, 2018).

Figure C-6. Dose-response curve for the Hill model fit to increased relative liver weight in male rats (NTP, 2018).

Figure C-7 User input for dose-response modeling of increased relative liver weight in male rats (NTP, 2018).

Figure C-7. User input for dose-response modeling of increased relative liver weight in male rats (NTP, 2018).

Figure C-8 Model results for increased relative liver weight in male rats (NTP, 2018).

Figure C-8. Model results for increased relative liver weight in male rats (NTP, 2018).

Table C-24 Benchmark dose results for increased relative liver weight in male rats—constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.3381 | 0.2930 | <0.0001 | 314.8501 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (CV – normal) | Restricted | 0.3381 | 0.2930 | <0.0001 | 314.8501 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (CV – normal) | Restricted | 0.1486 | 0.1209 | 0.2654 | 291.5391 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.1485 | 0.1209 | 0.2653 | 291.5398 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.1460 | 0.1169 | 0.2774 | 291.4313 | Viable – Recommended | Lowest AIC
Polynomial (5 degree) (CV – normal) | Restricted | 0.2202 | 0.1909 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (CV – normal) | Restricted | 0.2202 | 0.1976 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (CV – normal) | Restricted | 0.2202 | 0.1894 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (CV – normal) | Restricted | 0.2202 | 0.1894 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (CV – normal) | Restricted | 0.2202 | 0.1894 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (CV – normal) | Unrestricted | 0.2202 | 0.1894 | 0.0115 | 298.5321 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

### C.2.6 Increased Relative Liver Weight – Female Rat (NTP, 2018)

Table C-25 Dose-response data for increased relative liver weight in female rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 33.52 | 2.37
0.156 | 10 | 37.66 | 2.81
0.312 | 10 | 40.08 | 1.77
0.625 | 10 | 44.25 | 2.59
1.25 | 10 | 50.84 | 2.12
2.5 | 10 | 67.75 | 2.85

Table C-26 Benchmark dose results for increased relative liver weight in female rats – BMR = constant variance, 10% relative deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.3761 | 0.3585 | 0.0005 | 297.3583 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (CV – normal) | Restricted | 0.3761 | 0.3585 | 0.0005 | 297.3583 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (CV – normal) | Restricted | 0.2457 | 0.2042 | 0.0512 | 287.1715 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 5 (CV – normal) | Restricted | 0.2456 | 0.2042 | 0.0512 | 287.1717 | Questionable | Goodness-of-fit p-value < 0.1
Hill (CV – normal) | Restricted | 0.2446 | 0.2018 | 0.0518 | 287.1453 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (5 degree) (CV – normal) | Restricted | 0.2688 | 0.2545 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (CV – normal) | Restricted | 0.2688 | 0.2528 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (CV – normal) | Restricted | 0.2688 | 0.2524 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (CV – normal) | Restricted | 0.2688 | 0.2524 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (CV – normal) | Restricted | 0.2688 | 0.2524 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (CV – normal) | Unrestricted | 0.2688 | 0.2524 | 0.0764 | 285.8573 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Table C-27 Benchmark dose results for increased relative liver weight in female rats – nonconstant variance, BMR = 10% relative deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 0.3779 | 0.3586 | 0.0005 | 299.1741 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (NCV – normal) | Restricted | 0.3779 | 0.3586 | 0.0005 | 299.1741 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (NCV – normal) | Restricted | 0.2443 | 0.2017 | 0.0468 | 289.1376 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 5 (NCV – normal) | Restricted | 0.2464 | 0.2016 | 0.0466 | 289.1432 | Questionable | Goodness-of-fit p-value < 0.1
Hill (NCV – normal) | Restricted | 0.2431 | 0.1997 | 0.0474 | 289.1075 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (5 degree) (NCV – normal) | Restricted | 0.2688 | 0.2519 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (NCV – normal) | Restricted | 0.2688 | 0.2519 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (NCV – normal) | Restricted | 0.2688 | 0.2521 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (NCV – normal) | Restricted | 0.2688 | 0.2521 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (NCV – normal) | Restricted | 0.2688 | 0.2521 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (NCV – normal) | Unrestricted | 0.2688 | 0.2521 | 0.0695 | 287.8570 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Table C-28 Benchmark dose results for increased relative liver weight in female rats – log-normal, constant variance, BMR = 10% relative deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – log-normal) | Restricted | 0.3617 | 0.3404 | <0.0001 | 304.9243 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 3 (CV – log-normal) | Restricted | 0.3617 | 0.3404 | <0.0001 | 304.9243 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 4 (CV – log-normal) | Restricted | 0.2228 | 0.1850 | <0.0001 | 291.5746 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Exponential 5 (CV – log-normal) | Restricted | 0.2228 | 0.1850 | <0.0001 | 291.5746 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Hill (CV – g-normal) | Restricted | 0.2200 | 0.1800 | <0.0001 | 291.4503 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (5 degree) (CV – log-normal) | Restricted | 0.2622 | 0.2441 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (4 degree) (CV – log-normal) | Restricted | 0.2622 | 0.2454 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (3 degree) (CV – log-normal) | Restricted | 0.2622 | 0.2433 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Polynomial (2 degree) (CV – log-normal) | Restricted | 0.2622 | 0.2433 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Power (CV – log-normal) | Restricted | 0.2622 | 0.2433 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2
Linear (CV – log-normal) | Unrestricted | 0.2622 | 0.2433 | <0.0001 | 291.8437 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; \|Residual at control\| > 2

Table C-29 Benchmark dose results for increased relative liver weight in female rats, high dose dropped – BMR = constant variance, 10% relative deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.3195 | 0.2902 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (CV – normal) | Restricted | 0.3195 | 0.2902 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (CV – normal) | Restricted | 0.1611 | 0.1214 | 0.5849 | 231.5654 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.1610 | 0.1214 | 0.5849 | 231.5654 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.1544 | 0.1117 | 0.6566 | 231.3342 | Viable – Recommended | Lowest AIC
Polynomial (5 degree) (CV – normal) | Restricted | 0.2659 | 0.2374 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (CV – normal) | Restricted | 0.2659 | 0.2374 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (CV – normal) | Restricted | 0.2659 | 0.2374 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (CV – normal) | Restricted | 0.2659 | 0.2374 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (CV – normal) | Restricted | 0.2659 | 0.2374 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (CV – normal) | Unrestricted | 0.3195 | 0.2902 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

Figure C-9 Dose-response curve for the Hill model fit to increased relative liver weight in female rats with the highest dose dropped (NTP, 2018).

Figure C-9. Dose-response curve for the Hill model fit to increased relative liver weight in female rats with the highest dose dropped (NTP, 2018).

Figure C-10 User input for dose-response modeling of increased relative liver weight in female rats with highest dose dropped (NTP, 2018).

Figure C-10. User input for dose-response modeling of increased relative liver weight in female rats with highest dose dropped (NTP, 2018).

Figure C-11 Model results for increased relative liver weight in female rats with highest dose dropped (NTP, 2018).

Figure C-11. Model results for increased relative liver weight in female rats with highest dose dropped (NTP, 2018).

Table C-30 Benchmark dose results for increased relative liver weight in female rats, high dose dropped – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 10% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.2341 | 0.1980 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 3 (CV – normal) | Restricted | 0.2341 | 0.1980 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Exponential 4 (CV – normal) | Restricted | 0.1050 | 0.0785 | 0.5849 | 231.5654 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.1049 | 0.0785 | 0.5849 | 231.5654 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.1000 | 0.0722 | 0.6566 | 231.3342 | Viable – Recommended | Lowest AIC
Polynomial (5 degree) (CV – normal) | Restricted | 0.1854 | 0.1675 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (4 degree) (CV – normal) | Restricted | 0.1854 | 0.1553 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (3 degree) (CV – normal) | Restricted | 0.1854 | 0.1553 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Polynomial (2 degree) (CV – normal) | Restricted | 0.1854 | 0.1553 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Power (CV – normal) | Restricted | 0.1854 | 0.1553 | 0.0308 | 237.3809 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2
Linear (CV – normal) | Unrestricted | 0.2341 | 0.1980 | 0.0031 | 242.3745 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual at control\| > 2

### C.2.7 Increased Relative Liver Weight (Histopathology cohort) – Female Rats (Frawley et al., 2018)

Table C-31 Dose-response data for increased relative liver weight (Histopathology cohort) in female rats (Frawley et al., 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 8 | 4.02 | 0.28
0.125 | 8 | 4.06 | 0.28
0.25 | 8 | 4.35 | 0.28
0.5 | 8 | 4.68 | 0.34

Table C-32 Benchmark dose results for increased relative liver weight (Histopathology cohort) in female rats – constant variance, BMR = 10% relative deviation (Frawley et al., 2018)

Models | Restriction | 10% Relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.2929 | 0.2224 | 0.6024 | 15.6701 | Viable – Recommended | Lowest AIC
Exponential 3 (CV – normal) | Restricted | 0.3215 | 0.2240 | 0.3551 | 17.5116 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.2823 | 0.1647 | 0.2944 | 17.7557 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.2729 | 0.1840 | NA | 18.6564 | Questionable | d.f. = 0, saturated model (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 0.2777 | 0.1901 | NA | 18.6564 | Questionable | d.f. = 0, saturated model (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.3170 | 0.2099 | 0.3338 | 17.5904 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.3170 | 0.2099 | 0.3338 | 17.5904 | Viable – Alternate
Power (CV – normal) | Restricted | 0.3195 | 0.2113 | 0.3675 | 17.4686 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.2824 | 0.2081 | 0.5775 | 15.7543 | Viable – Alternate

Figure C-12 Dose-response curve for the Exponential 2 model fit to increased relative liver weight (Histopathology cohort) in female rats (Frawley et al., 2018).

Figure C-12. Dose-response curve for the Exponential 2 model fit to increased relative liver weight (Histopathology cohort) in female rats (Frawley et al., 2018).

Figure C-13 User input for dose-response modeling of increased relative liver weight (Histo) in female rats (Frawley et al., 2018).

Figure C-13. User input for dose-response modeling of increased relative liver weight (Histo) in female rats (Frawley et al., 2018).

Figure C-14 Model results for increased relative liver weight (Histopathology cohort) in female rats (Frawley et al., 2018).

Figure C-14. Model results for increased relative liver weight (Histopathology cohort) in female rats (Frawley et al., 2018).

Table C-33 Benchmark dose results for increased relative liver weight (Histopathology cohort) in female rats – constant variance, BMR = 1 standard deviation (Frawley et al., 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.2100 | 0.1561 | 0.6024 | 15.6701 | Viable – Recommended | Lowest AIC
Exponential 3 (CV – normal) | Restricted | 0.2405 | 0.1572 | 0.3551 | 17.5116 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.2003 | 0.1453 | 0.2944 | 17.7557 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.2332 | 0.1314 | NA | 18.6564 | Questionable | d.f. = 0, saturated model (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 0.2310 | 0.1312 | NA | 18.6564 | Questionable | d.f. = 0, saturated model (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.2343 | 0.1467 | 0.3338 | 17.5904 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.2343 | 0.1467 | 0.3338 | 17.5904 | Viable – Alternate
Power (CV – normal) | Restricted | 0.2394 | 0.1476 | 0.3675 | 17.4686 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.2005 | 0.1455 | 0.5775 | 15.7543 | Viable – Alternate

### C.2.8 Increased Relative Liver Weight (MPS cohort) – Female Rats (Frawley et al., 2018)

Table C-34 Dose-response data for increased relative liver weight (MPS cohort) in female rats (Frawley et al., 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 8 | 3.42 | 0.26
0.125 | 8 | 3.77 | 0.28
0.25 | 8 | 3.86 | 0.26
0.5 | 8 | 4.19 | 0.17

Table C-35 Benchmark dose results for increased relative liver weight (Histopathology cohort) in female rats – constant variance, BMR = 10% relative deviation (Frawley et al., 2018)

Models | Restriction | 10% Relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.2575 | 0.2036 | 0.2714 | 5.4499 | Viable – Alternate
Exponential 3 (CV – normal) | Restricted | 0.2575 | 0.2044 | 0.2714 | 5.4499 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.1644 | 0.0852 | 0.3121 | 5.8634 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.1646 | 0.0851 | 0.3121 | 5.8634 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.1587 | 0.0730 | 0.3336 | 5.7766 | Viable – Alternate
Polynomial (3 degree) (CV – normal) | Restricted | 0.2419 | 0.1864 | 0.3283 | 5.0691 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.2419 | 0.1864 | 0.3283 | 5.0691 | Viable – Alternate
Power (CV – normal) | Restricted | 0.2419 | 0.1864 | 0.3283 | 5.0691 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.2419 | 0.1864 | 0.3283 | 5.0691 | Viable – Recommended | Lowest AIC

Figure C-15 Dose-response curve for the Linear model fit to increased relative liver weight (MPS) in female rats (Frawley et al., 2018).

Figure C-15. Dose-response curve for the Linear model fit to increased relative liver weight (MPS) in female rats (Frawley et al., 2018).

Figure C-16 User input for dose-response modeling of increased relative liver weight (MPS cohort) in female rats (Frawley et al., 2018).

Figure C-16. User input for dose-response modeling of increased relative liver weight (MPS cohort) in female rats (Frawley et al., 2018).

Figure C-17 Model results for increased relative liver weight (MPS cohort) in female rats (Frawley et al., 2018).

Figure C-17. Model results for increased relative liver weight (MPS cohort) in female rats (Frawley et al., 2018).

Table C-36 Benchmark dose results for increased relative liver weight (MPS cohort) in female rats – constant variance, BMR = 1 standard deviation (Frawley et al., 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.1788 | 0.1367 | 0.2714 | 5.4499 | Viable – Alternate
Exponential 3 (CV – normal) | Restricted | 0.1788 | 0.1367 | 0.2714 | 5.4499 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.1046 | 0.0549 | 0.3121 | 5.8634 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.1048 | 0.0549 | 0.3121 | 5.8634 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.0994 | 0.0450 | 0.3336 | 5.7766 | Viable – Recommended | Lowest BMDL
Polynomial (3 degree) (CV – normal) | Restricted | 0.1651 | 0.1238 | 0.3283 | 5.0691 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.1651 | 0.1238 | 0.3283 | 5.0691 | Viable – Alternate
Power (CV – normal) | Restricted | 0.1651 | 0.1238 | 0.3283 | 5.0691 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.1651 | 0.1238 | 0.3283 | 5.0691 | Viable – Alternate

### C.2.9 Increased Relative Liver Weight (TDAR to SRBC cohort) – Female Rats (Frawley et al., 2018)

Table C-37 Dose-response data for increased relative liver weight (TDAR to SRBC cohort) in female rats (Frawley et al., 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 8 | 3.85 | 0.14
0.125 | 8 | 3.94 | 0.11
0.25 | 8 | 4.6 | 0.37
0.5 | 8 | 5.21 | 0.28

Table C-38 Benchmark dose results for increased relative liver weight (TDAR to SRBC cohort) in female rats – constant variance, BMR = 10% relative deviation (Frawley et al., 2018)

Models | Restriction | 10% Relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.1478 | 0.1295 | 0.0284 | 10.5539 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 3 (CV – normal) | Restricted | 0.1541 | 0.1297 | 0.0077 | 12.5248 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 4 (CV – normal) | Restricted | 0.1294 | 0.0935 | 0.0073 | 12.6257 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 5 (CV – normal) | Restricted | 0.1951 | 0.1458 | NA | 7.4299 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev. d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 0.1904 | 0.1497 | NA | 7.4299 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev. d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.1419 | 0.1108 | 0.0079 | 12.4766 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (2 degree) (CV – normal) | Restricted | 0.1419 | 0.1108 | 0.0079 | 12.4766 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Power (CV – normal) | Restricted | 0.1556 | 0.1124 | 0.0103 | 12.0114 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Linear (CV – normal) | Unrestricted | 0.1295 | 0.1103 | 0.0274 | 10.6256 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2; Modeled control response std. dev. > \|1.5\| actual response std. dev.

Table C-39 Benchmark dose results for increased relative liver weight (TDAR to SRBC cohort) in female rats – nonconstant variance, BMR = 10% relative deviation (Frawley et al., 2018)

Models | Restriction | 10% Relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 0.1478 | 0.1284 | 0.0012 | 10.0543 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2
Exponential 3 (NCV – normal) | Restricted | 0.1607 | 0.1292 | 0.0003 | 11.8202 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2
Exponential 4 (NCV – normal) | Restricted | 0.1333 | 0.1030 | 0.0002 | 12.4411 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2
Exponential 5 (NCV – normal) | Restricted | 0.1937 | 0.1654 | NA | 0.5572 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (NCV – normal) | Restricted | 0.1880 | 0.1653 | NA | 0.5577 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (NCV – normal) | Restricted | 0.1507 | 0.1144 | 0.0002 | 11.9784 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2
Polynomial (2 degree) (NCV – normal) | Restricted | 0.1507 | 0.1144 | 0.0002 | 11.9784 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2
Power (NCV – normal) | Restricted | 0.1628 | 0.1183 | 0.0004 | 11.0771 | Questionable | Goodness-of-fit p-value < 0.1
Linear (NCV – normal) | Unrestricted | 0.1334 | 0.1127 | 0.0010 | 10.4397 | Questionable | Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2

Table C-40 Benchmark dose results for increased relative liver weight (TDAR to SRBC cohort) in female rats – log-normal, constant variance, BMR = 10% relative deviation (Frawley et al., 2018)

Models | Restriction | 10% Relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Log-normal Constant variance
Exponential 2 (CV – log-normal) | Restricted | 0.1478 | 0.1295 | 0.0172 | 7.4633 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 3 (CV – log-normal) | Restricted | 0.1639 | 0.1304 | 0.0050 | 9.2051 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 4 (CV – log-normal) | Restricted | 0.1315 | 0.1026 | 0.0033 | 9.9692 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 5 (CV – log-normal) | Restricted | 0.1644 | 0.1111 | NA | 10.6210 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev.; d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (CV – log-normal) | Restricted | 0.1918 | 0.1692 | NA | 3.3425 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev.; d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – log-normal) | Restricted | 0.1541 | 0.1143 | 0.0046 | 9.3729 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Polynomial (2 degree) (CV – log-normal) | Restricted | 0.1541 | 0.1143 | 0.0046 | 9.3729 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Power (CV – log-normal) | Restricted | 0.1649 | 0.1176 | 0.0070 | 8.6207 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Linear (CV – log-normal) | Unrestricted | 0.1315 | 0.1122 | 0.0134 | 7.9687 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.

### C.2.10 Decreased Fetal Weight – Male and Female Rats (Harris and Birnbaum, 1989)

Table C-41 Dose-response data for decreased fetal weight in male and female rats (Harris and Birnbaum, 1989)

Dose (mg/kg-d) | n | Mean | SD
0 | 86.4 | 1.17 | 0.09
0.03 | 85.8 | 1.16 | 0.19^a^
0.1 | 94.8 | 1.13 | 0.2
0.3 | 102 | 1.16 | 0.3
1 | 103.6 | 1.12 | 0.2
3 | 87.6 | 1.1 | 0.09
6.4 | 75.4 | 0.9 | 0.26
12.8 | 32.2 | 0.59 | 0.11

a Value adjusted in September 2024. The Harris and Birnbaum (1989) paper reported a standard error of 0.02 from which a standard deviation of 0.19 was calculated. Originally, a standard error of 0.002 was used in the calculations. This adjusted model results displayed in Tables C-42 to C-44.

Table C-42 Benchmark dose results for decreased fetal weight in male and female rats – constant variance, BMR = 5% relative deviation (Harris and Birnbaum, 1989)

Models | Restriction | 5% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.1862 | 1.0639 | 0.0028 | −226.0932 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 3 (CV – normal) | Restricted | 2.4442 | 1.8596 | 0.4254 | −239.1267 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Exponential 4 (CV – normal) | Restricted | 1.1862 | 1.0639 | 0.0028 | −226.0932 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 5 (CV – normal) | Restricted | 2.9886 | 1.9712 | 0.4106 | −238.0831 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Hill (CV – normal) | Restricted | 3.0454 | 1.9113 | 0.4026 | −238.0241 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (7 degree) (CV – normal) | Restricted | 1.9190 | 1.4443 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (6 degree) (CV – normal) | Restricted | 1.9190 | 1.4449 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (5 degree) (CV – normal) | Restricted | 1.9189 | 1.4443 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (4 degree) (CV – normal) | Restricted | 1.9190 | 1.4444 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (3 degree) (CV – normal) | Restricted | 1.9190 | 1.4477 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Polynomial (2 degree) (CV – normal) | Restricted | 1.9190 | 1.4674 | 0.2567 | −237.5033 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Power (CV – normal) | Restricted | 2.1850 | 1.5984 | 0.3253 | −238.2406 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std.; dev. >\|1.5\| actual response std. dev.
Linear (CV – normal) | Unrestricted | 1.3815 | 1.2682 | 0.0744 | −234.5619 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.

Table C-43 Benchmark dose results for decreased fetal weight in male and female rats – nonconstant variance, BMR = 5% relative deviation (Harris and Birnbaum, 1989)

Models | Restriction | 5% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 1.1683 | 1.0516 | 0.0009 | −224.6812 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 3 (NCV – normal) | Restricted | 2.5190 | 1.9453 | 0.5075 | −241.1100 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 4 (NCV – normal) | Restricted | 1.1685 | 1.0515 | 0.0009 | −224.6808 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 5 (NCV – normal) | Restricted | 2.6116 | 1.9470 | 0.3692 | −239.1251 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Hill (NCV – normal) | Restricted | 2.5867 | 1.7751 | 0.3674 | −239.1102 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (7 degree) (NCV – normal) | Restricted | 1.9985 | 1.4672 | 0.4047 | −240.3145 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (6 degree) (NCV – normal) | Restricted | 1.9975 | 1.4705 | 0.4048 | −240.3151 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (5 degree) (NCV – normal) | Restricted | 1.9989 | 1.4711 | 0.4047 | −240.3143 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (4 degree) (NCV – normal) | Restricted | 1.9975 | 1.4760 | 0.4048 | −240.3151 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (3 degree) (NCV – normal) | Restricted | 1.9975 | 1.4906 | 0.4048 | −240.3151 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Polynomial (2 degree) (NCV – normal) | Restricted | 1.9975 | 1.5338 | 0.4048 | −240.3151 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Power (NCV – normal) | Restricted | 2.2611 | 1.6859 | 0.4694 | −240.8278 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Linear (NCV – normal) | Unrestricted | 1.3574 | 1.2604 | 0.0568 | −235.1657 | Questionable | Non-constant variance test failed (Test 3 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.

Table C-44 Benchmark dose results for decreased fetal weight in male and female rats – log-normal, constant variance, BMR = 5% relative deviation (Harris and Birnbaum, 1989)

Models | Restriction | 5% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Log-normal, constant variance
Exponential 2 (CV – log-normal) | Restricted | 1.0548 | 0.9782 | <0.0001 | −244.9575 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 3 (CV – log-normal) | Restricted | 2.2130 | 1.7263 | 0.0606 | −262.4338 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 4 (CV – log-normal) | Restricted | 1.0548 | 0.9782 | <0.0001 | −244.9575 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness of fit p-value < 0.1; Modeled control response std. dev. >\|1.5\| actual response std. dev.
Exponential 5 (CV – log-normal) | Restricted | 3.5276 | 2.4889 | 0.2537 | −265.6587 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. >\|1.5\| actual response std. dev.
Hill (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (7 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (6 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (5 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (4 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (3 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (2 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Power (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Linear (CV – log-normal) | Unrestricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution

### C.2.11 Decreased Sperm Count – Male Rats (NTP, 2018)

Table C-45 Dose-response data for decreased sperm counts in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 136.3 | 32.26
0.625 | 10 | 120.8 | 17.39
1.25 | 10 | 112.9 | 23.09
2.5 | 10 | 95.7 | 36.37

Table C-46 Benchmark dose results for decreased sperm counts in male rats, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.5928 | 0.9634 | 0.9331 | 382.8116 | Viable – Recommended | Lowest AIC
Exponential 3 (CV – normal) | Restricted | 1.5928 | 0.9634 | 0.9331 | 382.8116 | Viable – Recommended | Lowest AIC
Exponential 4 (CV – normal) | Restricted | 1.4241 | 0.5083 | 0.8023 | 384.7359 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 1.4241 | 0.5083 | 0.8023 | 384.7359 | Viable – Alternate
Hill (CV – normal) | Restricted | 1.4208 | 0.4347 | 0.8120 | 384.7298 | Viable – Alternate
Polynomial (3 degree) (CV – normal) | Restricted | 1.7202 | 1.1328 | 0.8756 | 382.9388 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 1.7202 | 1.1328 | 0.8756 | 382.9388 | Viable – Alternate
Power (CV – normal) | Restricted | 1.7202 | 1.1329 | 0.8756 | 382.9388 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 1.7202 | 1.1328 | 0.8756 | 382.9388 | Viable – Alternate

Figure C-18 Dose-response curve for the Exponential 2 model fit to decreased sperm counts in male rats (NTP, 2018).

Figure C-18. Dose-response curve for the Exponential 2 model fit to decreased sperm counts in male rats (NTP, 2018).

Figure C-19 User input for dose-response modeling of decreased sperm counts in male rats (NTP, 2018).

Figure C-19. User input for dose-response modeling of decreased sperm counts in male rats (NTP, 2018).

Figure C-20 Model results for decreased sperm counts in male rats (NTP, 2018).

Figure C-20. Model results for decreased sperm counts in male rats (NTP, 2018).

### C.2.12 Decreased Absolute Testis Weight – Male Rats (NTP, 2018)

Table C-47 Dose-response data for decreased absolute testis weight in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 9 | 1.777 | 0.17
0.156 | 10 | 1.797 | 0.15
0.312 | 10 | 1.742 | 0.12
0.625 | 10 | 1.74 | 0.1
1.25 | 10 | 1.695 | 0.11
2.5 | 10 | 1.553 | 0.2

Table C-48 Benchmark dose results for decreased absolute testis weight in male rats – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.4763 | 1.0220 | 0.9324 | −59.4936 | Viable – Alternate
Exponential 3 (CV – normal) | Restricted | 1.7052 | 1.0373 | 0.8973 | −57.7417 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 1.4763 | 1.0220 | 0.9324 | −59.4936 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 1.7049 | 0.8202 | 0.7420 | −55.7409 | Viable – Alternate
Hill (CV – normal) | Restricted | 1.7088 | 0.8010 | 0.7448 | −55.7486 | Viable – Alternate
Polynomial (5 degree) (CV – normal) | Restricted | 1.7976 | 1.0880 | 0.9114 | −57.8041 | Viable – Alternate
Polynomial (4 degree) (CV – normal) | Restricted | 1.7750 | 1.0878 | 0.9107 | −57.8008 | Viable – Alternate
Polynomial (3 degree) (CV – normal) | Restricted | 1.7482 | 1.0873 | 0.9089 | −57.7926 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 1.7214 | 1.0861 | 0.9046 | −57.7738 | Viable – Alternate
Power (CV – normal) | Restricted | 1.7089 | 1.0848 | 0.8995 | −57.7514 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 1.5110 | 1.0742 | 0.9430 | −59.5723 | Viable – Recommended | Lowest AIC

Figure C-21 Dose-response curve for the Linear model fit to decreased absolute testis weight in male rats (NTP, 2018).

Figure C-21. Dose-response curve for the Linear model fit to decreased absolute testis weight in male rats (NTP, 2018).

Figure C-22 User input for dose-response modeling of decreased absolute testis weight in male rats (NTP, 2018).

Figure C-22. User input for dose-response modeling of decreased absolute testis weight in male rats (NTP, 2018).

Figure C-23 Model results for decreased absolute testis weight in male rats (NTP, 2018).

Figure C-23. Model results for decreased absolute testis weight in male rats (NTP, 2018).

### C.2.13 Decreased Absolute Caudal Epididymis Weight – Male Rats (NTP, 2018)

Table C-49 Dose-response data for decreased absolute caudal epididymis weight in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 0.184 | 0.02
0.625 | 10 | 0.178 | 0.01
1.25 | 10 | 0.164 | 0.02
2.5 | 10 | 0.138 | 0.03

Table C-50 Benchmark dose results for decreased absolute caudal epididymis weight in male rats – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.9906 | 0.7014 | 0.6614 | −192.1231 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 3 (CV – normal) | Restricted | 1.2840 | 0.7347 | 0.7934 | −190.8813 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 4 (CV – normal) | Restricted | 0.9906 | 0.7014 | 0.6614 | −192.1231 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 5 (CV – normal) | Restricted | 1.2550 | 0.6841 | NA | −188.9499 | Questionable | Constant variance test failed (Test 2 p-value < 0.05) d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 1.2551 | 0.6802 | NA | −188.9499 | Questionable | Constant variance test failed (Test 2 p-value < 0.05) d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 1.2961 | 0.8004 | 0.6972 | −190.7984 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (2 degree) (CV – normal) | Restricted | 1.2961 | 0.8004 | 0.6972 | −190.7984 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Power (CV – normal) | Restricted | 1.2924 | 0.8027 | 0.7563 | −190.8535 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Linear (CV – normal) | Unrestricted | 1.0647 | 0.7868 | 0.7835 | −192.4618 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)

Table C-51 Benchmark dose results for decreased absolute caudal epididymis weight in male rats – nonconstant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (NCV – normal) | Restricted | 0.7898 | 0.5327 | 0.3071 | −193.9474 | Viable – Alternate
Exponential 3 (NCV – normal) | Restricted | 1.1440 | 0.6331 | 0.5123 | −193.8789 | Viable – Alternate
Exponential 4 (NCV – normal) | Restricted | 0.7902 | 0.5326 | 0.3070 | −193.9463 | Viable – Alternate
Exponential 5 (NCV – normal) | Restricted | 1.1558 | 0.6708 | NA | −192.3083 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculatedd)
Hill (NCV – normal) | Restricted | 1.1495 | 0.6702 | NA | −192.3080 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (NCV – normal) | Restricted | 1.1618 | 0.6304 | 0.4150 | −193.6438 | Viable – Alternate
Polynomial (2 degree) (NCV – normal) | Restricted | 1.1618 | 0.6304 | 0.4150 | −193.6438 | Viable – Alternate
Power (NCV – normal) | Restricted | 1.1497 | 0.6390 | 0.4771 | −193.8028 | Viable – Alternate
Linear (NCV – normal) | Unrestricted | 0.8363 | 0.5824 | 0.4086 | −194.5183 | Viable – Recommended | Lowest AIC

Figure C-24 Dose-response curve for the Linear model fit to decreased absolute caudal epididymis weight in male rats (NTP, 2018).

Figure C-24. Dose-response curve for the Linear model fit to decreased absolute caudal epididymis weight in male rats (NTP, 2018).

Figure C-25 User Input for dose-response modeling of decreased caudal epididymis weight in male rats (NTP, 2018).

Figure C-25. User Input for dose-response modeling of decreased caudal epididymis weight in male rats (NTP, 2018).

Figure C-26 Model results for decreased caudal epididymis weight in male rats (NTP, 2018).

Figure C-26. Model results for decreased caudal epididymis weight in male rats (NTP, 2018).

### C.2.14 Decreased Absolute Whole Epididymis Weight – Male Rats (NTP, 2018)

Table C-52 Dose-response data for decreased absolute whole epididymis weight in male rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 0.528 | 0.05
0.625 | 10 | 0.508 | 0.03
1.25 | 10 | 0.474 | 0.04
2.5 | 10 | 0.407 | 0.08

Table C-53 Benchmark dose results for decreased whole caudal epididymis weight in male rats – constant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.9572 | 0.6866 | 0.7614 | −118.5715 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 3 (CV – normal) | Restricted | 1.2024 | 0.7076 | 0.8891 | −117.0973 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 4 (CV – normal) | Restricted | 0.9572 | 0.6866 | 0.7614 | −118.5715 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Exponential 5 (CV – normal) | Restricted | 1.2024 | 0.7076 | 0.8891 | −117.0973 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Hill (CV – normal) | Restricted | 1.1911 | 0.6254 | NA | −115.1168 | Questionable | Constant variance test failed (Test 2 p-value < 0.05) d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 1.2061 | 0.7720 | 0.7980 | −117.0513 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (2 degree) (CV – normal) | Restricted | 1.2061 | 0.7720 | 0.7980 | −117.0513 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Power (CV – normal) | Restricted | 1.2076 | 0.7732 | 0.8530 | −117.0825 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Linear (CV – normal) | Unrestricted | 1.0266 | 0.7639 | 0.8678 | −118.8333 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)

Table C-54 Benchmark dose results for decreased absolute whole epididymis weight in male rats – nonconstant variance, BMR = 1 standard deviation (NTP, 2018)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (NCV – normal) | Restricted | 0.7358 | 0.5033 | 0.3609 | −121.3235 | Viable – Alternate
Exponential 3 (NCV – normal) | Restricted | 1.0959 | 0.5980 | 0.7979 | −121.2963 | Viable – Alternate
Exponential 4 (NCV – normal) | Restricted | 0.7360 | 0.5033 | 0.3609 | −121.3235 | Viable – Alternate
Exponential 5 (NCV – normal) | Restricted | 1.0960 | 0.5986 | NA | −119.2989 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (NCV – normal) | Restricted | 1.1035 | 0.6011 | NA | −119.3619 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (NCV – normal) | Restricted | 1.1012 | 0.5975 | 0.6702 | −121.1805 | Viable – Alternate
Polynomial (2 degree) (NCV – normal) | Restricted | 1.1012 | 0.5974 | 0.6702 | −121.1805 | Viable – Alternate
Power (NCV – normal) | Restricted | 1.0965 | 0.6018 | 0.7557 | −121.2651 | Viable – Alternate
Linear (NCV – normal) | Unrestricted | 0.7766 | 0.5458 | 0.4809 | −121.8975 | Viable – Recommended | Lowest AIC

Figure C-27 Dose-response curve for the Linear model fit to decreased absolute whole epididymis weight in male rats (NTP, 2018).

Figure C-27. Dose-response curve for the Linear model fit to decreased absolute whole epididymis weight in male rats (NTP, 2018).

Figure C-28 User input for dose-response modeling of decreased absolute whole epididymis weight in male rats (NTP, 2018).

Figure C-28. User input for dose-response modeling of decreased absolute whole epididymis weight in male rats (NTP, 2018).

Figure C-29 Model results for decreased absolute whole epididymis weight in male rats (NTP, 2018).

Figure C-29. Model results for decreased absolute whole epididymis weight in male rats (NTP, 2018).

### C.2.15 Decreased Days in Estrus – Female Rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Table C-55 Dose-response data for decreased days in estrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 5.5 | 1.5092
0.625 | 10 | 4.3 | 2.0575
1.25 | 10 | 3.2 | 1.8136
2.5 | 10 | 0.9 | 0.9944

Table C-56 Benchmark dose results for decreased days in estrus in female rats – constant variance, BMR = 5% relative deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 5% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.0923 | 0.0687 | 0.3592 | 157.0377 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Exponential 3 (CV – normal) | Restricted | 0.2611 | 0.0778 | 0.6119 | 157.2473 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Exponential 4 (CV – normal) | Restricted | 0.0923 | 0.0687 | 0.3592 | 157.0377 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Exponential 5 (CV – normal) | Restricted | 0.2608 | 0.0776 | 0.6119 | 157.2473 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Hill (CV – normal) | Restricted | 0.1487 | 0.0739 | NA | 158.9967 | Questionable | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose; d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.1495 | 0.1283 | 0.9965 | 154.9969 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Polynomial (2 degree) (CV – normal) | Restricted | 0.1495 | 0.1283 | 0.9965 | 154.9969 | Viable – Recommended | Lowest AIC; BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Power (CV – normal) | Restricted | 0.1495 | 0.1283 | 0.9965 | 154.9969 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Linear (CV – normal) | Unrestricted | 0.1495 | 0.1283 | 0.9965 | 154.9969 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose

Figure C-30 Dose-response curve for the Polynomial 2 model fit to decreased days in estrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007).

Figure C-30. Dose-response curve for the Polynomial 2 model fit to decreased days in estrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007).

Figure C-31 User input for dose-response modeling of decreased days in estrus in female rats (NTP, 2018).

Figure C-31. User input for dose-response modeling of decreased days in estrus in female rats (NTP, 2018).

Figure C-32 Model results for decreased days in estrus in female rats (NTP, 2018).

Figure C-32. Model results for decreased days in estrus in female rats (NTP, 2018).

Table C-57 Benchmark dose results for decreased days in estrus in female rats – constant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.5895 | 0.3889 | 0.3592 | 157.0377 | Viable – Alternate
Exponential 3 (CV – normal) | Restricted | 0.8806 | 0.4576 | 0.6119 | 157.2473 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.5895 | 0.3889 | 0.3592 | 157.0377 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.8804 | 0.4576 | 0.6119 | 157.2473 | Viable – Alternate
Hill (CV – normal) | Restricted | 0.8393 | 0.4491 | NA | 158.9967 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.8500 | 0.6520 | 0.9965 | 154.9969 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.8500 | 0.6520 | 0.9965 | 154.9969 | Viable – Recommended | Lowest AIC
Power (CV – normal) | Restricted | 0.8500 | 0.6520 | 0.9965 | 154.9969 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.8500 | 0.6520 | 0.9965 | 154.9969 | Viable – Alternate

### C.2.16 Increased Days in Diestrus – Female Rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Table C-58 Dose-response data for increased days in diestrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 9.2 | 1.874
0.625 | 10 | 10.1 | 2.1833
1.25 | 10 | 11.7 | 2.2632
2.5 | 10 | 15 | 1.0541

Table C-59 Benchmark dose results for increased days in diestrus in female rats – constant variance, BMR = 5% relative deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 5% relative deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.2430 | 0.2000 | 0.9231 | 167.0076 | Viable – Recommended | Lowest AIC; BMDL 3× lower than lowest nonzero dose
Exponential 3 (CV – normal) | Restricted | 0.2891 | 0.2006 | 0.7433 | 168.9548 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Exponential 4 (CV – normal) | Restricted | 0.1870 | 0.1136 | 0.4064 | 169.5368 | Viable – Alternate | BMD 3× lower than lowest nonzero dose; BMDL 3× lower than lowest nonzero dose
Exponential 5 (CV – normal) | Restricted | 0.4063 | 0.1241 | NA | 170.8476 | Questionable | BMDL 3× lower than lowest nonzero dose; d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 0.4079 | 0.1226 | NA | 170.8476 | Questionable | BMDL 3× lower than lowest nonzero dose; d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.2770 | 0.1470 | 0.7388 | 168.9588 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Polynomial (2 degree) (CV – normal) | Restricted | 0.2770 | 0.1470 | 0.7388 | 168.9588 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Power (CV – normal) | Restricted | 0.3283 | 0.1475 | 0.8200 | 168.8993 | Viable – Alternate | BMDL 3× lower than lowest nonzero dose
Linear (CV – normal) | Unrestricted | 0.1872 | 0.1427 | 0.7099 | 167.5330 | Viable – Alternate | BMD 3× lower than lowest nonzero dose

Figure C-33 Dose-response curve for the Exponential 2 model fit to increased days in diestrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007).

Figure C-33. Dose-response curve for the Exponential 2 model fit to increased days in diestrus in female rats (Butenhoff et al., 2012; van Otterdijk, 2007).

Figure C-34 User input for dose-response modeling of increased days in diestrus in female rats (NTP, 2018).

Figure C-34. User input for dose-response modeling of increased days in diestrus in female rats (NTP, 2018).

Figure C-35 Model results for increased days in diestrus in female rats (NTP, 2018).

Figure C-35. Model results for increased days in diestrus in female rats (NTP, 2018).

Table C-60 Benchmark dose results for increased days in diestrus in female rats – constant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.9064 | 0.7377 | 0.9231 | 167.0076 | Viable – Recommended | Lowest AIC
Exponential 3 (CV – normal) | Restricted | 0.9766 | 0.7391 | 0.7433 | 168.9548 | Viable – Alternate
Exponential 4 (CV – normal) | Restricted | 0.7661 | 0.5970 | 0.4064 | 169.5368 | Viable – Alternate
Exponential 5 (CV – normal) | Restricted | 0.9947 | 0.5599 | NA | 170.8476 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Hill (CV – normal) | Restricted | 0.9936 | 0.5580 | NA | 170.8476 | Questionable | d.f. = 0, saturated model; (Goodness-of-fit p value cannot be calculated)
Polynomial (3 degree) (CV – normal) | Restricted | 0.9687 | 0.6117 | 0.7388 | 168.9588 | Viable – Alternate
Polynomial (2 degree) (CV – normal) | Restricted | 0.9687 | 0.6117 | 0.7388 | 168.9588 | Viable – Alternate
Power (CV – normal) | Restricted | 0.9805 | 0.6134 | 0.8200 | 168.8993 | Viable – Alternate
Linear (CV – normal) | Unrestricted | 0.7667 | 0.5963 | 0.7099 | 167.5330 | Viable – Alternate

### C.2.17 Decreased Relative Uterine Weight – Female Rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Table C-61 Dose-response data for decreased relative uterine weight in female rats (Butenhoff et al., 2012; van Otterdijk, 2007))

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 3.26 | 1.3
0.156 | 10 | 2.73 | 0.41
0.312 | 10 | 2.94 | 0.79
0.625 | 10 | 3.65 | 1.68
1.25 | 10 | 2.05 | 0.61
2.5 | 10 | 1.81 | 0.32

Table C-62 Benchmark dose results for decreased relative uterine weight in female rats – BMR = constant variance, 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS Classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS Classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 1.6357 | 0.9728 | 0.0296 | 178.4420 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 3 (CV – normal) | Restricted | 1.8431 | 1.0220 | 0.0170 | 179.8915 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 4 (CV – normal) | Restricted | 1.6357 | 0.9728 | 0.0296 | 178.4420 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 5 (CV – normal) | Restricted | 1.2312 | 0.7036 | 0.1496 | 175.0232 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Hill (CV – normal) | Restricted | 1.2139 | 0.7285 | 0.1496 | 175.0233 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (5 degree) (CV – normal) | Restricted | 1.8244 | 1.2032 | 0.0147 | 180.2109 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (4 degree) (CV – normal) | Restricted | 1.8244 | 1.2032 | 0.0147 | 180.2109 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (3 degree) (CV – normal) | Restricted | 1.8244 | 1.2032 | 0.0147 | 180.2109 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (2 degree) (CV – normal) | Restricted | 1.8244 | 1.2032 | 0.0147 | 180.2109 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Power (CV – normal) | Restricted | 1.8813 | 1.2094 | 0.0153 | 180.1247 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Linear (CV – normal) | Unrestricted | 1.7547 | 1.2018 | 0.0324 | 178.2308 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1

Table C-63 Benchmark dose results for decreased relative uterine weight in female rats – nonconstant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 2.3599 | 1.4658 | <0.0001 | 168.8763 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 3 (NCV – normal) | Restricted | 2.4946 | 1.8929 | <0.0001 | 167.1138 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 4 (NCV – normal) | Restricted | 2.3592 | 1.4658 | <0.0001 | 168.8763 | Questionable | Goodness-of-fit p-value < 0.1
Exponential 5 (NCV – normal) | Restricted | 1.2787 | 1.1724 | 0.0011 | 157.4375 | Questionable | Goodness-of-fit p-value < 0.1
Hill (NCV – normal) | Restricted | 1.3094 | 1.1258 | 0.0011 | 157.4376 | Questionable | Goodness-of-fit p-value < 0.1
Polynomial (5 degree) (NCV – normal) | Restricted | 2.5118 | 1.9996 | <0.0001 | 165.4887 | Questionable | Goodness-of-fit p-value < 0.1; BMD higher than maximum dose
Polynomial (4 degree) (NCV – normal) | Restricted | 2.5118 | 1.9997 | <0.0001 | 165.4887 | Questionable | Goodness-of-fit p-value < 0.1; BMD higher than maximum dose
Polynomial (3 degree) (NCV – normal) | Restricted | 2.5118 | 1.9997 | <0.0001 | 165.4887 | Questionable | Goodness-of-fit p-value < 0.1; BMD higher than maximum dose
Polynomial (2 degree) (NCV – normal) | Restricted | 2.5118 | 1.9997 | <0.0001 | 165.4887 | Questionable | Goodness-of-fit p-value < 0.1; BMD higher than maximum dose
Power (NCV – normal) | Restricted | 2.5092 | 1.9643 | <0.0001 | 167.4725 | Questionable | Goodness-of-fit p-value < 0.1; BMD higher than maximum dose
Linear (NCV – normal) | Unrestricted | 2.4008 | 1.7105 | <0.0001 | 167.5269 | Questionable | Goodness-of-fit p-value < 0.1

Table C-64 Benchmark dose results for decreased relative uterine weight in female rats – log-normal, constant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – log-normal) | Restricted | 1.9961 | 0.9991 | 0.0518 | 147.6232 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 3 (CV – log-normal) | Restricted | 2.0457 | 1.0012 | 0.0249 | 149.5811 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 4 (CV – log-normal) | Restricted | 1.9491 | 0.6763 | 0.0246 | 149.6001 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 5 (CV – log-normal) | Restricted | 1.2532 | 0.6896 | 0.2457 | 145.0275 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Hill (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (5 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (4 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (3 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (2 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Power (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Linear (CV – log-normal) | Unrestricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution

### C.2.18 Decreased Absolute Uterine Weight – Female Rats (Butenhoff et al., 2012; van Otterdijk, 2007)

Table C-65 Dose-response data for decreased absolute uterine weight in female rats (NTP, 2018)

Dose (mg/kg-d) | n | Mean | SD
0 | 10 | 0.731 | 0.27
0.156 | 10 | 0.646 | 0.09
0.312 | 10 | 0.691 | 0.18
0.625 | 10 | 0.818 | 0.35
1.25 | 10 | 0.409 | 0.13
2.5 | 10 | 0.26 | 0.03

Table C-66 Benchmark dose results for decreased absolute uterine weight in female rats – BMR = constant variance, 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – normal) | Restricted | 0.8877 | 0.5920 | 0.0083 | −6.1338 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2
Exponential 3 (CV – normal) | Restricted | 1.2592 | 0.7971 | 0.0140 | −7.2318 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 4 (CV – normal) | Restricted | 0.8877 | 0.5920 | 0.0083 | −6.1338 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2
Exponential 5 (CV – normal) | Restricted | 1.2039 | 0.9713 | 0.2538 | −13.7789 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Hill (CV – normal) | Restricted | 1.1828 | 0.8675 | 0.1306 | −11.7788 | Questionable | Constant variance test failed (Test 2 p-value < 0.05)
Polynomial (5 degree) (CV – normal) | Restricted | 1.2569 | 0.8354 | 0.0076 | −5.9234 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (4 degree) (CV – normal) | Restricted | 1.2569 | 0.8354 | 0.0076 | −5.9234 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (3 degree) (CV – normal) | Restricted | 1.2569 | 0.8354 | 0.0076 | −5.9234 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (2 degree) (CV – normal) | Restricted | 1.2569 | 0.8354 | 0.0076 | −5.9234 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Power (CV – normal) | Restricted | 1.3086 | 0.8477 | 0.0088 | −6.2298 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1
Linear (CV – normal) | Unrestricted | 1.0823 | 0.8275 | 0.0163 | −7.7099 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1

Table C-67 Benchmark dose results for decreased absolute uterine weight in female rats – nonconstant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Nonconstant variance
Exponential 2 (NCV – normal) | Restricted | 1.3500 | 0.9186 | <0.0001 | −25.2943 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 3 (NCV – normal) | Restricted | 1.8175 | 1.3964 | <0.0001 | −33.2616 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for Dose Group Near BMD\| > 2
Exponential 4 (NCV – normal) | Restricted | 1.3502 | 0.9186 | <0.0001 | −25.2943 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Exponential 5 (NCV – normal) | Restricted | 1.2424 | 1.1367 | 0.0036 | −42.1526 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Hill (NCV – normal) | Restricted | 1.2387 | 1.1069 | 0.0103 | −44.1525 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (5 degree) (NCV – normal) | Restricted | 2.0088 | 1.5693 | 0.0001 | −33.9754 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (4 degree) (NCV – normal) | Restricted | 2.0088 | 1.5692 | 0.0001 | −33.9754 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (3 degree) (NCV – normal) | Restricted | 2.0088 | 1.5692 | 0.0001 | −33.9754 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Polynomial (2 degree) (NCV – normal) | Restricted | 2.0088 | 1.5692 | 0.0001 | −33.9754 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Power (NCV – normal) | Restricted | 1.9555 | 1.5188 | <0.0001 | −32.0845 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1
Linear (NCV – normal) | Unrestricted | 1.6526 | 1.2761 | <0.0001 | −30.8879 | Questionable | Nonconstant variance test failed (Test 3 p-value < 0.05); Goodness-of-fit p-value < 0.1; \|Residual for dose group near BMD\| > 2

Table C-68 Benchmark dose results for decreased absolute uterine weight in female rats – log-normal, constant variance, BMR = 1 standard deviation (Butenhoff et al., 2012; van Otterdijk, 2007)

Models | Restriction | 1 standard deviation | | p-Value | AIC | BMDS classification | BMDS notes
Models | Restriction | BMD | BMDL | p-Value | AIC | BMDS classification | BMDS notes
Constant variance
Exponential 2 (CV – log-normal) | Restricted | 1.0282 | 0.5795 | 0.0129 | −43.7584 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 3 (CV – log-normal) | Restricted | 1.2617 | 0.6141 | 0.0101 | −43.1248 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 4 (CV – log-normal) | Restricted | 1.0282 | 1.0189 | 0.0129 | −43.7584 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Goodness-of-fit p-value < 0.1; Modeled control response std. dev. > \|1.5\| actual response std. dev.
Exponential 5 (CV – log-normal) | Restricted | 1.2149 | 0.9197 | 0.3929 | −50.5863 | Questionable | Constant variance test failed (Test 2 p-value < 0.05); Modeled control response std. dev. > \|1.5\| actual response std. dev.
Hill (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (5 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (4 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (3 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Polynomial (2 degree) (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Power (CV – log-normal) | Restricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution
Linear (CV – log-normal) | Unrestricted | - | - | - | - | Unusable | BMD computation failed; Model was not run. Adverse direction “down” not compatible with log-normal distribution

1 Pooled variance for tetanus in 5-year-olds = [(502 − 1)(1.74)^2^ + (298 − 1)(1.17)^2^]/[502 + 298 − 2] = 2.41. The pooled SD is the square root of 2.41, which is 1.55 log_2_(IU/mL).

2 (Budtz-Jørgensen and Grandjean, 2018a) computed BMDs and BMDLs using a BMR of 5% decrease in the antibody concentrations. Their formula, BMD = log_2_(1-BMR)/β, can simply be reversed to solve for β = log_2_(1-BMR)/BMD. For negative dose response when more exposure results in lower antibody concentration, the BMDL is based on the lower bound of β, (β_LB_). Thus, the β_LB_ = log_2_(1-BMR)/BMDL. The SE(β) = (β - β_LB_)/1.645. The p-value is the two-sided probability that Z ≤ SE(β)/β.

3 Pooled variance for diphtheria in 5-year-olds = [(502 − 1)(2.22)^2^ + (298 − 1)(1.17)^2^]/[502 + 298 − 2] = 3.60. The pooled SD is the square root of 2.41, which is 1.90 log_2_(IU/mL).

4 While the explicit application of the hybrid approach is not commonly used in IRIS dose/concentration/exposure-response analyses, the more commonly used SD definition of the BMR for continuous data is simply one specific application of the hybrid approach. The SD definition of the BMR assumes the cutoff for adversity is the 1.4th percentile of a normally distributed response and shifting the mean of that distribution by 1 standard deviation approximates an extra risk of 10%.

5 Throughout this section, in the benchmark dose results tables, the “Restriction” column denotes the restriction status of applied models, and the “Classification” column denotes whether a model can be considered for model selection purposes. See BMDS User Guide: https://www.epa.gov/bmds. If a model was selected as appropriately fitting the modeled data, that model’s entries in the tables are in green shaded cells and the text is bolded.