# APPENDIX B ADDITIONAL DETAILS OF SYSTEMATIC REVIEW METHODS AND RESULTS

Table B-1 Summary of detailed search strategies for perfluorodecanoic acid and related salts (PubMed, Web of Science, Toxline, TSCATS, Toxcenter)

Search | Search strategy | Dates of search
PubMed
Search terms | 335–76-2[rn] OR “Ndfda”[tw] OR “Nonadecafluoro-n-decanoic acid”[tw] OR “Nonadecafluorodecanoic acid”[tw] OR “Perfluoro-n-decanoic acid”[tw] OR “Perfluorodecanoic acid”[tw] OR “2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-Decanoic acid”[tw] OR “Decanoic acid, 2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-“[tw] OR “Decanoic acid, nonadecafluoro-“[tw] OR “Perfluorodecanoate”[tw] OR “PFDeA”[tw] OR “PFDcA”[tw] OR (“PFDA”[tw] AND (fluorocarbon*[tw] OR fluorotelomer*[tw] OR polyfluoro*[tw] OR perfluoro-*[tw] OR perfluoroa*[tw] OR perfluorob*[tw] OR perfluoroc*[tw] OR perfluorod*[tw] OR perfluoroe*[tw] OR perfluoroh*[tw] OR perfluoron*[tw] OR B-1orB-1luoro*[tw] OR perfluorop*[tw] OR perfluoros*[tw] OR perfluorou*[tw] OR perfluorinated[tw] OR fluorinated[tw] OR PFAS[tw] OR PFOS[tw] OR PFOA[tw])) | No date limit–7/26/2017
Literature update search terms | ((335–76-2[rn] OR “Ndfda”[tw] OR “Nonadecafluoro-n-decanoic acid”[tw] OR “Nonadecafluorodecanoic acid”[tw] OR “Perfluoro-n-decanoic acid”[tw] OR “Perfluorodecanoic acid”[tw] OR “2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-Decanoic acid”[tw] OR “Decanoic acid, 2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-“[tw] OR “Decanoic acid, nonadecafluoro-“[tw] OR “Perfluorodecanoate”[tw] OR “PFDeA”[tw] OR “PFDcA”[tw] OR (“PFDA”[tw] AND (fluorocarbon*[tw] OR fluorotelomer*[tw] OR polyfluoro*[tw] OR perfluoro-*[tw] OR perfluoroa*[tw] OR perfluorob*[tw] OR perfluoroc*[tw] OR perfluorod*[tw] OR perfluoroe*[tw] OR perfluoroh*[tw] OR perfluoron*[tw] OR B-1orB-1luoro*[tw] OR perfluorop*[tw] OR perfluoros*[tw] OR perfluorou*[tw] OR perfluorinated[tw] OR fluorinated[tw] OR PFAS[tw] OR PFOS[tw] OR PFOA[tw])) AND (“2017/08/01”[Date – Publication] : “2018/03/01”[Date – Publication]) | Updates performed: February 2018, May 2019, May 2020, April 2021, April 2022, and April 2023 (this last update reflected in Appendix I)
Web of Science
Search terms | TS=”PFDeA” OR TS=”PFDcA” OR TS=”Ndfda” OR TS=”Nonadecafluoro-n-decanoic acid” OR TS=”Nonadecafluorodecanoic acid” OR TS=”Perfluoro-n-decanoic acid” OR TS=”Perfluorodecanoic acid” OR TS=”2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-Decanoic acid” OR TS=”Decanoic acid, 2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-“ OR TS=”Decanoic acid, nonadecafluoro-“ OR TS=”Perfluorodecanoate” OR (TS=PFDA AND TS=(fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro-* OR perfluoroa* OR perfluorob* OR perfluoroc* OR perfluorod* OR perfluoroe* OR perfluoroh* OR perfluoron* OR B-2orB-2luoro* OR perfluorop* OR perfluoros* OR perfluorou* OR perfluorinated OR fluorinated)) OR (TS=PFDA AND TS=(fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro-* OR perfluoroa* OR perfluorob* OR perfluoroc* OR perfluorod* OR perfluoroe* OR perfluoroh* OR perfluoron* OR B-2orB-2luoro* OR perfluorop* OR perfluoros* OR perfluorou* OR perfluorinated OR fluorinated OR PFAS OR PFOS OR PFOA | No date limit–7/26/2017
Literature update search terms | TS=”PFDeA” OR TS=”PFDcA” OR TS=”Ndfda” OR TS=”Nonadecafluoro-n-decanoic acid” OR TS=”Nonadecafluorodecanoic acid” OR TS=”Perfluoro-n-decanoic acid” OR TS=”Perfluorodecanoic acid” OR TS=”2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-Decanoic acid” OR TS=”Decanoic acid, 2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-“ OR TS=”Decanoic acid, nonadecafluoro-“ OR TS=”Perfluorodecanoate” OR (TS=PFDA AND TS=(fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro-* OR perfluoroa* OR perfluorob* OR perfluoroc* OR perfluorod* OR perfluoroe* OR perfluoroh* OR perfluoron* OR B-2orB-2luoro* OR perfluorop* OR perfluoros* OR perfluorou* OR perfluorinated OR fluorinated)) OR (TS=PFDA AND TS=(fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro-* OR perfluoroa* OR perfluorob* OR perfluoroc* OR perfluorod* OR perfluoroe* OR perfluoroh* OR perfluoron* OR B-2orB-2luoro* OR perfluorop* OR perfluoros* OR perfluorou* OR perfluorinated OR fluorinated OR PFAS OR PFOS OR PFOA)) AND PY=2017–2018 | Updates performed: February 2018, May 2019, May 2020, April 2021, April 2022, and April 2023 (this last update reflected in Appendix I)
Toxline
Search terms | ( 335–76-2 [rn] OR “2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluorodecanoic acid” OR “2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-decanoic acid” OR “decanoic acid 2,2, 3, 3, 4, 4, 5, 5, 6, 6, 7, 7, 8, 8, 9, 9, 10, 10, 10-nonadecafluoro-“ OR “decanoic acid nonadecafluoro-“ OR “nonadecafluoro-n-decanoic acid” OR “nonadecafluorodecanoic acid” OR “perfluoro-1-nonanecarboxylic acid” OR “perfluoro-n-decanoic acid” OR “perfluorocapric acid” OR “perfluorodecanoate” OR “perfluorodecanoic acid” OR “ndfda” OR “PFDeA” OR “PFDcA” OR ( pfda AND ( fluorocarbon* OR fluorotelomer* OR polyfluoro* OR perfluoro* OR perfluorinated OR fluorinated OR pfas OR pfos OR pfoa ) ) ) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org] | No date limit–7/21/2017
Literature update search terms | | Updates performed: February 2018 and May 2019
TSCATS
Search terms | 335–76-2[rn] AND TSCATS [org] | No date limit–7/21/2017