# APPENDIX A SYSTEMATIC REVIEW PROTOCOL FOR THE PFAS IRIS ASSESSMENTS

A single systematic review protocol was used to guide the development of five separate IRIS per- and polyfluoroalkyl substance (PFAS) assessments (i.e., perfluorobutanoic acid [PFBA], perfluorohexanoic acid [PFHxA], perfluorohexane sulfonate [PFHxS], perfluorononanoic acid [PFNA], and perfluorodecanoic acid [PFDA]). This Systematic Review Protocol for the PFAS IRIS Assessments was released for public comment and subsequently updated. The updated protocol and prior revisions can be found at the following location: https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065.