# ABBREVIATIONS AND ACRONYMS

ADHD: attention deficient hyperactivity disorder
ADME: absorption, distribution, metabolism, excretion
AGD: anogenital distance
AIC: Akaike’s information criterion
ALT: alanine aminotransferase
ALP: alkaline phosphatase
AR: androgen
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: area under the curve
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMI: body max index
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
BWT: birth weight
CA: chromosomal aberration
CASRN: Chemical Abstracts Service Registry Number
CDR: Chemical Reporting Data
CCTE: Center for Computational Toxicology and Exposure
CHO: Chinese hamster ovary (cell line cells)
CI: confidence interval
CL: confidence limit
CL_A_: clearance in animals
CL_H_: clearance in humans
Cmax: peak concentration
CNS: central nervous system
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
CS: cross-sectional study
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DDEFs: data-derived extrapolation factors
DMSO: dimethylsulfoxide
DNA: deoxyribonucleic acid
DSB: double-strand breaks
DTH: delayed-type-hypersensitivity
EPA: Environmental Protection Agency
ER: estrogen
F_abs_: fraction absorbed
FDA: Food and Drug Administration
FEV_1_: forced expiratory volume of 1 second
GA: gestational age
GD: gestation day
GDH: glutamate dehydrogenase
GFR: glomerular filtration rate
GGT: γ-glutamyl transferase
GLP: good laboratory practices
GSH: glutathione
GST: glutathione-S-transferase
HAWC: Health Assessment Workplace Collaborative
HBCD: hexabromocyclododecane
HCC: hepatocellular carcinoma
HFMD: hand, food, and mouth disease
Hb/g-A: animal blood: gas partition coefficient
Hb/g-H: human blood: gas partition coefficient
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
HR: hazard ratio
HTS: high-throughput screening
i.p.: intraperitoneal
IPCS: International Programme on Chemical Safety
IQR: interquartile range
IRIS: Integrated Risk Information System
i.v.: intravenous
LBW: low birth weight
LC_50_: median lethal concentration
LD_50_: median lethal dose
LDL: low-density lipoprotein
LOAEL: lowest-observed-adverse-effect level
LOD: limit of detection
LPS: lipopolysaccharide
MCH: mean corpuscular hemoglobin
MMR: measles, mumps, and rubella
MN: micronuclei
MNPCE: micronucleated polychromatic erythrocyte
MOA: mode of action
MPS: mononuclear phagocyte system
MRI: magnetic resonance imaging
MTD: maximum tolerated dose
NCEA: National Center for Environmental Assessment
NCI: National Cancer Institute
NHANES: National Health and Nutrition Examination Survey
NOAEL: no-observed-adverse-effect level
NR: not reported
NTP: National Toxicology Program
NZW: New Zealand white (rabbit breed)
ORD: Office of Research and Development
PBPK: physiologically based pharmacokinetic
PECO: population, exposure, comparator, outcome
PFAAs: perfluoroalkyl acids
PFAS: per and polyfluoroalkyl substances
PFBS: perfluorobutane sulfonic acid
PFCA: perfluoroalkylcarboxylic acids
PFDA: perfluorodecanoic acid
PFHxA: perfluorohexanoic acid
PFHxS: perfluorohexanesulfonic acid
PFNA: perfluorononanoic acid
PFOA: perfluorooctanoic acid
PFOS: perfluorooctane sulfonic acid
PK: pharmacokinetic
PND: postnatal day
POD: point of departure
POD_[ADJ]_: duration-adjusted POD
POD_HED_: human equivalent dose POD
PPARα: peroxisome proliferator-activator receptor alpha
PTB: preterm birth
QSAR: quantitative structure-activity relationship
RBC: red blood cells
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
RGDR: regional gas dose ratio
RNA: ribonucleic acid
ROS: reactive oxygen species
RR: relative risk
SAR: structure activity relationship
SCE: sister chromatid exchange
SD: standard deviation
SDH: sorbitol dehydrogenase
SDS: standard deviation scores
SE: standard error
SGA: small for gestational age
SGOT: glutamic oxaloacetic transaminase, also known as AST
SGPT: glutamic pyruvic transaminase, also known as ALT
SHBG: sex hormone binding globulin
SRBC: sheep red blood cell
Tmax: time to peak concentration
TNFα: tumor necrosis factor alpha
TRH: thyroid releasing hormone
TSCATS: Toxic Substances Control Act Test Submission
TSH: thyroid-stimulating hormone
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
VLBW: very low birth weight
WHO: World Health Organization
WOS: Web of Science