# REFERENCES

Abbaspour, N; Hurrell, R; Kelishadi, R. (2014). Review on iron and its importance for human health [Review]. J Res Med Sci 19: 164–174.24778671
ACC (American Chemistry Council). (2015). Pathology peer slide review of non-neoplastic findings in the duodenum of mice and rats treated with sdd in acc-ts and ntp studies.
Acharya, S; Mehta, K; Krishnan, S; Rao, CV. (2001). A subtoxic interactive toxicity study of ethanol and chromium in male Wistar rats. Alcohol 23: 99–108. 10.1016/S0741-8329(00)00139-7.11331107
Acharya, UR; Mishra, M; Mishra, I; Tripathy, RR. (2004). Potential role of vitamins in chromium induced spermatogenesis in Swiss mice. Environ Toxicol Pharmacol 15: 53–59. 10.1016/j.etap.2003.08.010.21782680
Acharya, UR; Mishra, M; Tripathy, RR; Mishra, I. (2006). Testicular dysfunction and antioxidative defense system of Swiss mice after chromic acid exposure. Reprod Toxicol 22: 87–91. 10.1016/j.reprotox.2005.11.004.16434167
Adachi, S. (1987). [Effects of chromium compounds on the respiratory system: Part 5. Long term inhalation of chromic acid mist in electroplating by C57BL female mice and recapitulation of our experimental studies]. Sangyo Igaku 29: 17–33. 10.1539/joh1959.29.17.3613247
Adachi, S; Yoshimura, H; Katayama, H; Takemoto, K. (1986). [Effects of chromium compounds on the respiratory system: Part 4. Long term inhalation of chromic acid mist in electroplating to ICR female mice]. Sangyo Igaku 28: 283–287. 10.1539/joh1959.28.283.3784105
Adachi, S; Yoshimura, H; Miyayama, R; Katayama, H; Takemoto, K; Kawai, H. (1981). [Effects of chromium compounds to the respiratory system: Part 1. An experimental study of inhalation of chromic acid mist in electroplating]. Sangyo Igaku 23: 294–299. 10.1539/joh1959.23.294.7277851
AEI (Applied Epidemiology Inc). (2002). Collaborative cohort mortality study of four chromate production facilities, 1958–1998: Final report. (8EHQ-0810–18050; OSHA Docket H054A Ex. 48–1–2). Pittsburgh, PA: Industrial Health Foundation. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0602411.xhtml.
Ahmad, MK; Syma, S; Mahmood, R. (2011). Cr(VI) Induces Lipid Peroxidation, Protein Oxidation and Alters the Activities of Antioxidant Enzymes in Human Erythrocytes. Biol Trace Elem Res 144: 426–435. 10.1007/s12011-011-9119-5.21681464
Akbar, M; Brewer, JM; Grant, MH. (2011). Effect of chromium and cobalt ions on primary human lymphocytes in vitro. J Immunotoxicol 8: 140–149. 10.3109/1547691X.2011.553845.21446789
Al-Hamood, MH; Elbetieha, A; Bataineh, H. (1998). Sexual maturation and fertility of male and female mice exposed prenatally and postnatally to trivalent and hexavalent chromium compounds. Reprod Fertil Dev 10: 179–183.9801270
Alao, JP. (2007). The regulation of cyclin D1 degradation: Roles in cancer development and the potential for therapeutic invention [Review]. Mol Cancer 6: 24. 10.1186/1476-4598-6-24.17407548
Alexander, J; Aaseth, J. (1995). Uptake of chromate in human red blood cells and isolated rat liver cells: the role of the anion carrier. Analyst 120: 931–933. 10.1039/AN9952000931.7741257
Alexander, J; Aaseth, J; Norseth, T. (1982). Uptake of chromium by rat liver mitochondria. Toxicology 24: 115–122. 10.1016/0300-483X(82)90050-6.7135409
Alexander, J; Mikalsen, A; Ryberg, D. (1986). Microsomal reduction of Cr VI. Acta Pharmacol Toxicol 59: 267–269. 10.1111/j.1600-0773.1986.tb02759.x.
Alexopoulos, EC; Cominos, X; Trougakos, IP; Lourda, M; Gonos, ES; Makropoulos, V. (2008). Biological monitoring of hexavalent chromium and serum levels of the senescence biomarker Apolipoprotein J/Clusterin in welders. Bioinorganic Chemistry and Applications 2008: 420578. 10.1155/2008/420578.18464919
Alguacil, J; Porta, M; Kauppinen, T; Malats, N; Kogevinas, M; Carrato, A; Grp, PIS. (2003). Occupational exposure to dyes, metals, polycyclic aromatic hydrocarbons and other agents and K-ras activation in human exocrine pancreatic cancer. Int J Cancer 107: 635–641. 10.1002/ijc.11431.14520703
Ali, AH; Kondo, K; Namura, T; Senba, Y; Takizawa, H; Nakagawa, Y; Toba, H; Kenzaki, K; Sakiyama, S; Tangoku, A. (2011). Aberrant DNA methylation of some tumor suppressor genes in lung cancers from workers with chromate exposure. Mol Carcinog 50: 89–99. 10.1002/mc.20697.21229606
Almaguer, D; Kramkowski, R. (1983). Health hazard evaluation report no. HETA-82–116-1319, Modine Manufacturing, McHenry, Illinois. Cincinnati, OH: National Institute for Occupational Safety and Health.
American Pregnancy Association. (2021). Anemia during pregnancy. Available online at https://americanpregnancy.org/healthy-pregnancy/pregnancy-concerns/anemia-duringpregnancy/ (accessed August 10, 2022).
Andersen, A; Barlow, L; Engeland, A; Kjaerheim, K; Lynge, E; Pukkala, E. (1999). Work-related cancer in the Nordic countries [Supplemental Data]. Scand J Work Environ Health 25: 1–116.
Anger, G; Halstenberg, J; Hochgeschwender, K; Scherhag, C; Korallus, U; Knopf, H; Schmidt, P; Ohlinger, M. (2005). Chromium compounds. In B Elvers (Ed.), Ullmann's Encyclopedia of Industrial Chemistry (7th ed., pp. 1–36). Hoboken, NJ: Wiley-VCH Verlag GmbH & Co. 10.1002/14356007.a07 067.
Antonini, JM; Lawryk, NJ; Murthy, GG; Brain, JD. (1999). Effect of welding fume solubility on lung macrophage viability and function in vitro. J Toxicol Environ Health A 58: 343–363. 10.1080/009841099157205.10580758
Antonini, JM; Roberts, JR; Chapman, RS; Soukup, JM; Ghio, AJ; Sriram, K. (2010a). Pulmonary toxicity and extrapulmonary tissue distribution of metals after repeated exposure to different welding fumes. Inhal Toxicol 22: 805–816. 10.3109/08958371003621641.20560776
Antonini, JM; Taylor, MD; Zimmer, AT; Roberts, JR. (2010b). Pulmonary responses to welding fumes: Role of metal constituents [Review]. J Toxicol Environ Health A 67: 233–249. 10.1080/15287390490266909.
Anwar, RA; Langham, RF; Hoppert, CA; Alfredson, BV; Byerrum, RU. (1961). Chronic toxicity studies: III. Chronic toxicity of cadmium and chromium in dogs. Arch Environ Health 3: 456–460.13861841
Aoki, Y; Matsumoto, M; Matsumoto, M; Masumura, K; Nohmi, T. (2019). Mutant frequency is not increased in mice orally exposed to sodium dichromate. Food Saf 7: 2–10. 10.14252/foodsafetyfscj.2018014.
Apte, AD; Tare, V; Bose, P. (2006). Extent of oxidation of Cr(III) to Cr(VI) under various conditions pertaining to natural environment. J Hazard Mater 128: 164–174. 10.1016/j.jhazmat.2005.07.057.16297546
Arakawa, H; Ahmad, R; Naoui, M; Tajmir-Riahi, HA. (2000). A comparative study of calf thymus DNA binding to Cr(III) and Cr(VI) ions. Evidence for the guanine N-7-chromium-phosphate chelate formation. J Biol Chem 275: 10150–10153.10744697
Arakawa, H; Weng, MW; Chen, WC; Tang, MS. (2012). Chromium (VI) induces both bulky DNA adducts and oxidative DNA damage at adenines and guanines in the p53 gene of human lung cells. Carcinogenesis 33: 1993–2000. 10.1093/carcin/bgs237.22791815
Arakawa, H; Wu, F; Costa, M; Rom, W; Tang, MS. (2006). Sequence specificity of Cr(III)-DNA adduct formation in the p53 gene: NGG sequences are preferential adduct-forming sites. Carcinogenesis 27: 639–645. 10.1093/carcin/bgi249.16251206
Arias, E; Heron, M; Xu, J. (2017). United States life tables, 2013. National Vital Statistics Reports; vol 66 no 3. Hyattsville, MD: National Center for Health Statistics.
Armienta-Hernández, MA; Rodríguez-Castillo, R. (1995). Environmental exposure to chromium compounds in the valley of León, México. Environ Health Perspect 103 Suppl 1: 47–51.
Arshad, M; Ahmad, N; Khalid, M; Asmatullah; Tahir, M; Naveed, K; Iqbal, A. (2017). Exposure of pregnant mice to hexavalent chromium causes fetal defects. Pakistan J Zool 49: 1383–1389. 10.17582/journal.pjz/2017.49.4.1383.1389.
Aruldhas, MM; Subramanian, S; Sekar, P; Vengatesh, G; Chandrahasan, G; Govindarajulu, P; Akbarsha, MA. (2005). Chronic chromium exposure-induced changes in testicular histoarchitecture are associated with oxidative stress: study in a non-human primate (Macaca radiata Geoffroy). Hum Reprod 20: 2801–2813. 10.1093/humrep/dei148.15980013
Aruldhas, MM; Subramanian, S; Sekhar, P; Hasan, GC; Govindarajulu, P; Akbarsha, MA. (2004). Microcanalization in the epididymis to overcome ductal obstruction caused by chronic exposure to chromium - a study in the mature bonnet monkey (Macaca radiata Geoffroy). Reproduction 128: 127–137. 10.1530/rep.1.00067.15232070
Aruldhas, MM; Subramanian, S; Sekhar, P; Vengatesh, G; Govindarajulu, P; Akbarsha, MA. (2006). In vivo spermatotoxic effect of chromium as reflected in the epididymal epithelial principal cells, basal cells, and intraepithelial macrophages of a nonhuman primate (Macaca radiata Geoffroy). Fertil Steril 86: 1097–1105. 10.1016/j.fertnstert.2006.03.025.16949592
Asatiani, N; Abuladze, M; Kartvelishvili, T; Kulikova, N; Asanishvili, L; Holman, HY; Sapojnikova, N. (2010). Response of antioxidant defense system to chromium (VI)-induced cytotoxicity in human diploid cells. Biometals 23: 161–172. 10.1007/s10534-009-9276-6.19915997
Asatiani, N; Kartvelishvili, T; Abuladze, M; Asanishvili, L; Sapojnikova, N. (2011). Chromium (VI) can activate and impair antioxidant defense system. Biol Trace Elem Res 142: 388–397. 10.1007/s12011-010-8806-y.20809274
Asatiani, N; Sapojnikova, N; Abuladze, M; Kartvelishvili, T; Kulikova, N; Kiziria, E; Namchevadze, E; Holman, HY. (2004). Effects of Cr(VI) long-term and low-dose action on mammalian antioxidant enzymes (an in vitro study). J Inorg Biochem 98: 490–496. 10.1016/j.jinorgbio.2003.12.014.14987850
Asgharian, B. (2004). A model of deposition of hygroscopic particles in the human lung. Aerosol Sci Technol 38: 938–947. 10.1080/027868290511236.
Asmatullah; Noreen, MA. (1999). Effect of oral administration of hexavalent chromium on total body weight, chromium uptake and histological structure of mouse liver. Punjab Univ J Zool 14: 53–63.
Atanassoff, PG; Brull, SJ; Weiss, BM; Landefeld, K; Alon, E; Rohling, R. (1995). The time course of gastric pH changes induced by omeprazole and ranitidine: A 24-hour dose-response study. Anesth Analg 80: 975–979. 10.1097/00000539-199505000-00021.7726442
ATS/ERS (American Thoracic Society and European Respiratory Society). (2019). Standardization of spirometry 2019 update. Am J Respir Crit Care Med 200: e70–e88. 10.1164/rccm.201908-1590ST.31613151
ATSDR (Agency for Toxic Substances and Disease Registry). (2005). Toxicological profile for nickel [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp15.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2012). Toxicological profile for chromium. Atlanta, GA: US Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=62&tid=17.
Axelsson, A; Persson, B. (1988). Determination of effective diffusion coefficients in calcium alginate gel plates with varying yeast cell content. Appl Biochem Biotechnol 18: 231–250.
Azad, N; Iyer, AK; Manosroi, A; Wang, L; Rojanasakul, Y. (2008). Superoxide-mediated proteasomal degradation of Bcl-2 determines cell susceptibility to Cr(VI)-induced apoptosis. Carcinogenesis 29: 1538–1545. 10.1093/carcin/bgn137.18544562
Bach, SP; Renehan, AG; Potten, CS. (2000). Stem cells: the intestinal stem cell as a paradigm [Review]. Carcinogenesis 21: 469–476. 10.1093/carcin/21.3.469.10688867
Badding, MA; Fix, NR; Antonini, JM; Leonard, SS. (2014). A Comparison of Cytotoxicity and Oxidative Stress from Welding Fumes Generated with a New Nickel-, Copper-Based Consumable versus Mild and Stainless Steel-Based Welding in RAW 264.7 Mouse Macrophages. PLoS ONE 9: e101310. 10.1371/journal.pone.0101310.24977413
Bagchi, D; Bagchi, M; Stohs, SJ. (2001). Chromium (VI)-induced oxidative stress, apoptotic cell death and modulation of p53 tumor suppressor gene. Mol Cell Biochem 222: 149–158. 10.1023/A:1017958028256.11678597
Bagchi, D; Balmoori, J; Bagchi, M; Ye, X; Williams, CB; Stohs, SJ. (2000). Role of p53 tumor suppressor gene in the toxicity of TCDD, endrin, naphthalene, and chromium (VI) in liver and brain tissues of mice. Free Radic Biol Med 28: 895–903. 10.1016/S0891-5849(00)00173-8.10802220
Bagchi, D; Balmoori, J; Bagchi, M; Ye, X; Williams, CB; Stohs, SJ. (2002). Comparative effects of TCDD, endrin, naphthalene and chromium (VI) on oxidative stress and tissue damage in the liver and brain tissues of mice. Toxicology 175: 73–82. 10.1016/S0300-483X(02)00062-8.12049837
Bagchi, D; Hassoun, EA; Bagchi, M; Muldoon, DF; Stohs, SJ. (1995a). Oxidative stress induced by chronic administration of sodium dichromate [Cr(VI)] to rats. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 110: 281–287. 10.1016/0742-8413(94)00103-H.7599977
Bagchi, D; Hassoun, EA; Bagchi, M; Stohs, SJ. (1995b). Chromium-induced excretion of urinary lipid metabolites, DNA damage, nitric oxide production, and generation of reactive oxygen species in Sprague-Dawley rats. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 110: 177–187. 10.1016/0742-8413(94)00093-P.7599967
Bagchi, D; Vuchetich, PJ; Bagchi, M; Hassoun, EA; Tran, MX; Tang, L; Stohs, SJ. (1997). Induction of oxidative stress by chronic administration of sodium dichromate [chromium VI] and cadmium chloride [cadmium II] to rats. Free Radic Biol Med 22: 471–478. 10.1016/s0891-5849(96)00352-8.8981039
Bai, JPF; Burckart, GJ; Mulberg, AE. (2016). Literature review of gastrointestinal physiology in the elderly, in pediatric patients, and in patients with gastrointestinal diseases [Review]. J Pharm Sci 105: 476–483. 10.1002/jps.24696.26539698
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Balachandar, V; Arun, M; Mohana Devi, S; Velmurugan, P; Manikantan, P; Karthick Kumar, A; Sasikala, K; Venkatesan, C. (2010). Evaluation of the genetic alterations in direct and indirect exposures of hexavalent chromium [Cr(VI)] in leather tanning industry workers North Arcot District, South India. Int Arch Occup Environ Health 83: 791–801. 10.1007/s00420-010-0562-y.20617332
Balashazy, I; Hofmann, W; Heistracher, T. (2003). Local particle deposition patterns may play a key role in the development of lung cancer. J Appl Physiol (1985) 94: 1719–1725. 10.1152/japplphysiol.00527.2002.12533493
Ban, M; Langonné, I; Goutet, M; Huguet, N; Pépin, E. (2010). Simultaneous analysis of the local and systemic immune responses in mice to study the occupational asthma mechanisms induced by chromium and platinum. Toxicology 277: 29–37. 10.1016/j.tox.2010.08.010.20732381
Banu, SK; Samuel, JB; Arosh, JA; Burghardt, RC; Aruldhas, MM. (2008). Lactational exposure to hexavalent chromium delays puberty by impairing ovarian development, steroidogenesis and pituitary hormone synthesis in developing Wistar rats. Toxicol Appl Pharmacol 232: 180–189. 10.1016/j.taap.2008.06.002.18602937
Banu, SK; Stanley, JA; Lee, J; Stephen, SD; Arosh, JA; Hoyer, PB; Burghardt, RC. (2011). Hexavalent chromium-induced apoptosis of granulosa cells involves selective sub-cellular translocation of Bcl-2 members, ERK1/2 and p53. Toxicol Appl Pharmacol 251: 253–266. 10.1016/j.taap.2011.01.011.21262251
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Barhoumi, R; Burghardt, RC. (2015). Identifying a novel role for X-prolyl aminopeptidase (Xpnpep) 2 in CrVI-induced adverse effects on germ cell nest breakdown and follicle development in rats. Biol Reprod 92: 67. 10.1095/biolreprod.114.125708.25568306
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Burghardt, RC. (2016). Resveratrol protects the ovary against chromium-toxicity by enhancing endogenous antioxidant enzymes and inhibiting metabolic clearance of estradiol. Toxicol Appl Pharmacol 303: 65–78. 10.1016/j.taap.2016.04.016.27129868
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Taylor, RJ; Burghardt, RC. (2017a). Chromium VI -Induced developmental toxicity of placenta is mediated through spatiotemporal dysregulation of cell survival and apoptotic proteins. Reprod Toxicol 68: 171–190. 10.1016/j.reprotox.2016.07.006.27443218
Banu, SK; Stanley, JA; Sivakumar, KK; Taylor, RJ; Arosh, JA; Burghardt, RC. (2017b). Editor's highlight: Exposure to CrVI during early pregnancy increases oxidative stress and disrupts the expression of antioxidant proteins in placental compartments. Toxicol Sci 155: 497–511. 10.1093/toxsci/kfw231.28077780
Banu, SK; Stanley, JA; Taylor, RJ; Sivakumar, KK; Arosh, JA; Zeng, L; Pennathur, S; Padmanabhan, V. (2018). Sexually Dimorphic Impact of Chromium Accumulation on Human Placental Oxidative Stress and Apoptosis. Toxicol Sci 161: 375–387. 10.1093/toxsci/kfx224.29069462
Baresic, M; Gornik, I; Radonic, R; Zlopasa, O; Gubarev, N; Gasparovic, V. (2009). Survival after severe acute chromic acid poisoning complicated with renal and liver failure. Intern Med 48: 711–715.19420819
Barnhart, J. (1997). Chromium chemistry and implications for environmental fate and toxicity. Journal of Soil Contamination 6: 561–568. 10.1080/15320389709383589.
Basak, O; van de Born, M; Korving, J; Beumer, J; van der Elst, S; van Es, JH; Clevers, H. (2014). Mapping early fate determination in Lgr5+ crypt stem cells using a novel Ki67-RFP allele. EMBO J 33: 2057–2068. 10.15252/embj.201488017.25092767
Bashandy, SAE; Ebaid, H; Al-Tamimi, J; Ahmed-Farid, OA; Omara, EA; Alhazza, IM. (2021). Melatonin Alleviated Potassium Dichromate-Induced Oxidative Stress and Reprotoxicity in Male Rats. BioMed Res Int 2021: 3565360. 10.1155/2021/3565360.34222468
Basketter, DA; Scholes, EW; Kimber, I. (1994). The performance of the local lymph node assay with chemicals identified as contact allergens in the human maximization test. Food Chem Toxicol 32: 543–547.8045461
Bataineh, H; Al-Hamood, MH; Elbetieha, A; Bani Hani, I. (1997). Effect of long-term ingestion of chromium compounds on aggression, sex behavior and fertility in adult male rat. Drug Chem Toxicol 20: 133–149. 10.3109/01480549709003875.9292274
Bataineh, HN; Bataineh, ZM; Daradka, H. (2007). Short-term exposure of female rats to industrial metal salts: Effect on implantation and pregnancy. Reproductive Medicine and Biology 6: 179–183. 10.1111/j.1447-0578.2007.00183.x.29699276
Beaumont, JJ; Sedman, RM; Reynolds, SD; Sherman, CD; Li, LH; Howd, RA; Sandy, MS; Zeise, L; Alexeeff, GV. (2008). Cancer mortality in a Chinese population exposed to hexavalent chromium in drinking water. Epidemiology 19: 12–23. 10.1097/EDE.0b013e31815cea4c.18091413
Bedinger, GM. (2015). 2014 Minerals yearbook. Arsenic [advance release]. Reston, VA: U.S. Geological Survey.
Bednar, CM; Kies, C. (1991). Inorganic contaminants in drinking water correlated with disease occurrence in Nebraska. J Am Water Resour Assoc 27: 631–635. 10.1111/j.1752-1688.1991.tb01464.x.
Behari, J; Chandra, SV; Tandon, SK. (1978). Comparative toxicity of trivalent and hexavalent chromium to rabbits III Biochemical and histological changes in testicular tissue. Biomed Biochim Acta 37: 463–468.
Behrens, T; Ge, C; Vermeulen, R; Kendzia, B; Olsson, A; Schüz, J; Kromhout, H; Pesch, B; Peters, S; Portengen, L; Gustavsson, P; Mirabelli, D; Guénel, P; Luce, D; Consonni, D; Caporaso, NE; Landi, MT; Field, JK; Karrasch, S; ... Brüning, T. (2023). Occupational exposure to nickel and hexavalent chromium and the risk of lung cancer in a pooled analysis of case-control studies (SYNERGY). Int J Cancer 152: 645–660. 10.1002/ijc.34272.36054442
Ben-David, U; Amon, A. (2020). Context is everything: aneuploidy in cancer [Review]. Nat Rev Genet 21: 44–62. 10.1038/s41576-019-0171-x.31548659
Benova, D; Hadjidekova, V; Hristova, R; Nikolova, T; Boulanova, M; Georgieva, I; Grigorova, M; Popov, T; Panev, T; Georgieva, R; Natarajan, AT; Darroudi, F; Nilsson, R. (2002). Cytogenetic effects of hexavalent chromium in Bulgarian chromium platers. Mutat Res 514: 29–38.11815242
Bessède, E; Dubus, P; Mégraud, F; Varon, C. (2015). Helicobacter pylori infection and stem cells at the origin of gastric cancer [Review]. Oncogene 34: 2547–2555. 10.1038/onc.2014.187.25043305
Betton, GR. (2013). A review of the toxicology and pathology of the gastrointestinal tract [Review]. Cell Biol Toxicol 29: 321–338. 10.1007/s10565-013-9257-y.23989862
Beyersmann, D; Hartwig, A. (2008). Carcinogenic metal compounds: Recent insight into molecular and cellular mechanisms [Review]. Arch Toxicol 82: 493–512. 10.1007/s00204-008-0313-y.18496671
Bick, RL; Girardi, TV; Lack, WJ; Costa, M; Titelbaum, D. (1996). Hodgkin's disease in association with hexavalent chromium exposure. Int J Hematol 64: 257–262.8923788
Birk, T; Mundt, KA; Dell, LD; Luippold, RS; Miksche, L; Steinmann-Steiner-Haldenstaett, W; Mundt, DJ. (2006). Lung cancer mortality in the German chromate industry, 1958 to 1998. J Occup Environ Med 48: 426–433. 10.1097/01.jom.0000194159.88688.f8.16607199
Bitterman, PB; Saltzman, LE; Adelberg, S; Ferrans, VJ; Crystal, RG. (1984). ALVEOLAR MACROPHAGE REPLICATION - ONE MECHANISM FOR THE EXPANSION OF THE MONONUCLEAR PHAGOCYTE POPULATION IN THE CHRONICALLY INFLAMED LUNG. J Clin Invest 74: 460–469. 10.1172/JCI111443.6746904
Blaser, H; Dostert, C; Mak, TW; Brenner, D. (2016). TNF and ROS Crosstalk in Inflammation [Review]. Trends Cell Biol 26: 249–261. 10.1016/j.tcb.2015.12.002.26791157
Błasiak, J; Trzeciak, A; Małecka-Panas, E; Drzewoski, J; Iwanienko, T; Szumiel, I; Wojewódzka, M. (1999). DNA damage and repair in human lymphocytes and gastric mucosa cells exposed to chromium and curcumin. Teratog Carcinog Mutagen 19: 19–31. 10.1002/(SICI)1520-6866(1999)19:1>19::AID-TCM3>3.0.CO;2-H.10321407
Bloomfield, JJ; Blum, W. (1928). Health hazards in chromium plating. Public Health Rep 43: 527–528. 10.2307/4578958.
Boland, CR; Goel, A. (2010). Microsatellite instability in colorectal cancer [Review]. Gastroenterology 138: 2073–2087.e2073. 10.1053/j.gastro.2009.12.064.20420947
Bonassi, S; Coskun, E; Ceppi, M; Lando, C; Bolognesi, C; Burgaz, S; Holland, N; Kirsh-Volders, M; Knasmueller, S; Zeiger, E; Carnesoltas, D; Cavallo, D; da Silva, J; de Andrade, VM; Demircigil, GC; Domínguez Odio, A; Donmez-Altuntas, H; Gattas, G; Giri, A; Giri, S; Gómez-Meda, B; Gómez-Arroyo, S; Hadjidekova, V; Haveric, A; Kamboj, M; Kurteshi, K; Martino-Roth, MG; Montero Montoya, R; Nersesyan, A; Pastor-Benito, S; Favero Salvadori, DM; Shaposhnikova, A; Stopper, H; Thomas, P; Torres-Bugarín, O; Yadav, AS; Zúñiga González, G; Fenech, M. (2011a). The HUman MicroNucleus project on eXfoLiated buccal cells (HUMN(XL)): the role of life-style, host factors, occupational exposures, health status, and assay protocol [Review]. Mutat Res 728: 88–97. 10.1016/j.mrrev.2011.06.005.21763453
Bonassi, S; El-Zein, R; Bolognesi, C; Fenech, M. (2011b). Micronuclei frequency in peripheral blood lymphocytes and cancer risk: evidence from human studies [Review]. Mutagenesis 26: 93–100. 10.1093/mutage/geq075.21164188
Bonassi, S; Norppa, H; Ceppi, M; Stromberg, U; Vermeulen, R; Znaor, A; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Gundy, S; Hansteen, IL; Knudsen, LE; Lazutka, J; Rossner, P; Sram, RJ; Boffetta, P. (2008). Chromosomal aberration frequency in lymphocytes predicts the risk of cancer: results from a pooled cohort study of 22 358 subjects in 11 countries. Carcinogenesis 29: 1178–1183. 10.1093/carcin/bgn075.18356148
Bonassi, S; Znaor, A; Ceppi, M; Lando, C; Chang, WP; Holland, N; Kirsch-Volders, M; Zeiger, E; Ban, S; Barale, R; Bigatti, MP; Bolognesi, C; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Hagmar, L; Joksic, G; Martelli, A; Migliore, L; Mirkova, E; Scarfi, MR; Zijno, A; Norppa, H; Fenech, M. (2007). An increased micronucleus frequency in peripheral blood lymphocytes predicts the risk of cancer in humans. Carcinogenesis 28: 625–631. 10.1093/carcin/bgl177.16973674
Bonde, JP. (1990). Semen quality and sex hormones among mild steel and stainless steel welders: A cross sectional study. Br J Ind Med 47: 508–514.2118383
Bonde, JP; Ernst, E. (1992). Sex hormones and semen quality in welders exposed to hexavalent chromium. Hum Exp Toxicol 11: 259–263.1354973
Bonin, MP; Flower, WL; Renzi, RF; Peng, LW. (1995). Size and concentration measurements of particles produced in commercial chromium plating processes. J Air Waste Manag Assoc 45: 902–907. 10.1080/10473289.1995.10467422.
Boone, L; Meyer, D; Cusick, P; Ennulat, D; Bolliger, AP; Everds, N; Meador, V; Elliott, G; Honor, D; Bounous, D; Jordan, H. (2005). Selection and interpretation of clinical pathology indicators of hepatic injury in preclinical studies [Review]. Vet Clin Pathol 34: 182–188. 10.1111/j.1939-165X.2005.tb00041.x.16134065
Boorman, G; Dixon, D; Elwell, M; Kerlin, R; Morton, D; Peters, T; Regan, K; Sullivan, J; Group, SHW. (2003). Assessment of hyperplastic lesions in rodent carcinogenicity studies. Toxicol Pathol 31: 709–710.14585740
Borella, P; Bargellini, A. (1993). Effects of trace elements on immune system: results in cultured human lymphocytes. J Trace Elem Med Biol 7: 231–233.
Borges, KM; Boswell, JS; Liebross, RH; Wetterhahn, KE. (1991). Activation of chromium(VI) by thiols results in chromium(V) formation, chromium binding to DNA and altered DNA conformation. Carcinogenesis 12: 551–561. 10.1093/carcin/12.4.551.1849467
Borneff, J; Engelhardt, K; Griem, W; Kunte, H; Reichert, J. (1968). Kanzerogene substanzen in wasser und boden. XXII. Mäusentränkversuch mit 3,4-benzpyren und kaliumchromat. [Kanzerogene substanzen in wasser und boden. XXII. Mäusentränkversuch mit 3,4-benzpyren und kaliumchromat]. Archiv fuer Hygiene und Bakteriologie 152: 45–53.
Boscolo, P; Di Gioacchino, M; Bavazzano, P; White, M; Sabbioni, E. (1997). Effects of chromium on lymphocyte subsets and immunoglobulins from normal population and exposed workers. Life Sci 60: 1319–1325. 10.1016/S0024-3205(96)00669-8.9096252
Bourne, HG, Jr; Yee, HT. (1950). Occupational cancer in a chromate plant - an environmental appraisal. Ind Med Surg 19: 563–567.14794219
Bovet, P; Lob, M; Grandjean, M. (1977). Spirometric alterations in workers in the chromium electroplating industry. Int Arch Occup Environ Health 40: 25–32. 10.1007/BF00435514.914372
Brandt-Rauf, P. (2006). Editorial retraction. Cancer mortality in a Chinese population exposed to hexavalent chromium in water. J Occup Environ Med 48: 749. 10.1097/00043764-200607000-00019.16832233
Braver, ER; Infante, P; Chu, K. (1985). An analysis of lung cancer risk from exposure to hexavalent chromium. Birth Defects Res B Dev Reprod Toxicol 5: 365–378.
Bridgewater, LC; Manning, FC; Patierno, SR. (1994). Base-specific arrest of in vitro DNA replication by carcinogenic chromium: relationship to DNA interstrand crosslinking. Carcinogenesis 15: 2421–2427. 10.1093/carcin/15.11.2421.7955085
Bright, P; Burge, PS; O'Hickey, SP; Gannon, PF; Robertson, AS; Boran, A. (1997). Occupational asthma due to chrome and nickel electroplating. Thorax 52: 28–32.9039236
Brilliant, MH; Gondo, Y; Eicher, EM. (1991). Direct molecular identification of the mouse pink-eyed unstable mutation by genome scanning. Science 252: 566–569. 10.1126/science.1673574.1673574
Brito, F; Ascanio, J; Mateo, S; Hernández, C; Araujo, L; Gili, P; Martín-Zarza, P; Domínguez, S; Mederos, A. (1997). Equilibria of chromate(VI) species in acid medium and ab initio studies of these species. Polyhedron 16: 3835–3846. 10.1016/S0277-5387(97)00128-9.
Brown, S; Lockart, MM; Thomas, CS; Bowman, MK; Woski, SA; Vincent, JB. (2020). Molecular Structure of Binary Chromium(III)-DNA Adducts. Chembiochem 21: 628–631. 10.1002/cbic.201900436.31472032
Browning, CL; Qin, Q; Kelly, DF; Prakash, R; Vanoli, F; Jasin, M; Wise, JP. (2016). Prolonged Particulate Hexavalent Chromium Exposure Suppresses Homologous Recombination Repair in Human Lung Cells. Toxicol Sci 153: 70–78. 10.1093/toxsci/kfw103.27449664
Browning, CL; Wise, JP. (2017). Prolonged exposure to particulate chromate inhibits RAD51 nuclear import mediator proteins. Toxicol Appl Pharmacol 331: 101–107. 10.1016/j.taap.2017.05.030.28554658
Browning, J; Gannon, BJ; O'Brien, P. (1983). The microvasculature and gastric luminal pH of the forestomach of the rat: A comparison with the glandular stomach. Int J Microcirc Clin Exp 2: 109–118.6678841
Bruno, M; Ross, J; Ge, Y. (2016). Proteomic responses of BEAS-2B cells to nontoxic and toxic chromium: Protein indicators of cytotoxicity conversion. Toxicol Lett 264: 59–70. 10.1016/j.toxlet.2016.08.025.27592090
Bryant, HE; Ying, S; Helleday, T. (2006). Homologous recombination is involved in repair of chromium-induced DNA damage in mammalian cells. Mutat Res 599: 116–123. 10.1016/j.mrfmmm.2006.02.001.16564059
Buerge, IJ; Hug, SJ. (1997). Kinetics and pH dependence of chromium(VI) reduction by iron(II). Environ Sci Technol 31: 1426–1432.
Burdsall, DP; Flores, HC; Krueger, J; Garretson, S; Gorbien, MJ; Iacch, A; Dobbs, V; Homa, T. (2013). Use of proton pump inhibitors with lack of diagnostic indications in 22 Midwestern US skilled nursing facilities. J Am Med Dir Assoc 14: 429–432. 10.1016/j.jamda.2013.01.021.23583000
Burke, T; Fagliano, J; Goldoft, M; Hazen, RE; Iglewicz, R; Mckee, T. (1991). Chromite ore processing residue in Hudson County, New Jersey. Environ Health Perspect 92: 131–137.1935843
Burton, ED; Choppala, G; Karimian, N; Johnston, SG. (2019). A new pathway for hexavalent chromium formation in soil: Fire-induced alteration of iron oxides. Environ Pollut 247: 618–625. 10.1016/j.envpol.2019.01.094.30711817
Caglieri, A; Goldoni, M; De Palma, G; Mozzoni, P; Gemma, S; Vichi, S; Testai, E; Panico, F; Corradi, M; Tagliaferri, S; Costa, LG. (2008). Exposure to low levels of hexavalent chromium: target doses and comparative effects on two human pulmonary cell lines. Acta Biomed 79 Suppl 1: 104–115.18924316
Calder, L. (1988). Chromium contamination of groundwater. In JO Nriagu; E Nieboer (Eds.), Chromium in the natural and human environments (pp. 215–229). New York, NY: Wiley. https://www.wiley.com/en-us/Chromium+in+the+Natural+and+Human+Environments+-p-9780471856436.
CalEPA (California Environmental Protection Agency). (2003). Ambient air monitoring for hexavalent chromium and metals in Barrio Logan: May 2001 through May 2002. (Report: 2003–10-14). Sacramento, CA.
CalEPA (California Environmental Protection Agency). (2004). Barrio Logan report: A compilation of air quality studies in Barrio Logan. November 2004. (Report: 2005–11-00). Sacramento, CA.
CalEPA (California Environmental Protection Agency). (2011). Public health goal for Hexavalent Chromium (Cr VI) in drinking water. Sacramento, CA: Pesticide and Environmental Toxicology Branch, Office of Environmental Health Hazard Assessment. http://oehha.ca.gov/media/downloads/water/public-health-goal/cr6phg072911.pdf.
CARB (California Air Resources Board). (2004). Neighborhood scale monitoring in Barrio Logan. (Paper 70255). Sacramento, CA.
Carette, D; Perrard, MH; Prisant, N; Gilleron, J; Pointis, G; Segretain, D; Durand, P. (2013). Hexavalent chromium at low concentration alters Sertoli cell barrier and connexin 43 gap junction but not claudin-11 and N-cadherin in the rat seminiferous tubule culture model. Toxicol Appl Pharmacol 268: 27–36. 10.1016/j.taap.2013.01.016.23357549
Carlisle, DL; Pritchard, DE; Singh, J; Owens, BM; Blankenship, LJ; Orenstein, JM; Patierno, SR. (2000). Apoptosis and P53 induction in human lung fibroblasts exposed to chromium (VI): Effect of ascorbate and tocopherol. Toxicol Sci 55: 60–68. 10.1093/toxsci/55.1.60.10788560
Carney, EW; Kimmel, CA. (2007). Interpretation of skeletal variations for human risk assessment: Delayed ossification and wavy ribs. Birth Defects Res B Dev Reprod Toxicol 80: 473–496. 10.1002/bdrb.20133.18157903
Casadevall, M; da Cruz Fresco, P; Kortenkamp, A. (1999). Chromium(VI)-mediated DNA damage: oxidative pathways resulting in the formation of DNA breaks and abasic sites. Chem Biol Interact 123: 117–132.10597905
Casteleyn, C; Rekecki, A; Van der Aa, A; Simoens, P; Van den Broeck, W. (2010). Surface area assessment of the murine intestinal tract as a prerequisite for oral dose translation from mouse to man. Lab Anim 44: 176–183. 10.1258/la.2009.009112.20007641
Cavallo, D; Ursini, CL; Fresegna, AM; Ciervo, A; Maiello, R; Rondinone, B; D'Agata, V; Iavicoli, S. (2010). Direct-oxidative DNA damage and apoptosis induction in different human respiratory cells exposed to low concentrations of sodium chromate. J Appl Toxicol 30: 218–225. 10.1002/jat.1487.19839025
Ceballos, D; West, C; Methner, M; Gong, W. (2017). Health hazard evaluation report: HHE-2013–0011-3278, May 2017. Evaluation of chromium, hexavalent chromium, cadmium, and isocyanate exposures in an African refinishing plant. (HHE-2013–0011-3278). National Institute for Occupational Safety and Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2017102698.xhtml.
Ceballos, D; West, C; Methner, M; Gong, W. (2019). Hexavalent Chromium Exposure and Nasal Tissue Effects at a Commercial Aircraft Refinishing Facility. J Occup Environ Med 61: e69–e73. 10.1097/JOM.0000000000001510.30507787
CGARN (Cancer Genome Atlas Research Network). (2012). Comprehensive genomic characterization of squamous cell lung cancers. Nature 489: 519–525. 10.1038/nature11404.22960745
CGARN (Cancer Genome Atlas Research Network). (2014). Comprehensive molecular characterization of gastric adenocarcinoma. Nature 513: 202–209. 10.1038/nature13480.25079317
CGARN (Cancer Genome Atlas Research Network). (2018a). Comparative molecular analysis of gastrointestinal adenocarcinomas. Cancer Cell 33: 721–735. 10.1016/j.ccell.2018.03.010.29622466
CGARN (Cancer Genome Atlas Research Network). (2018b). The immune landscape of cancer. Immunity 48: 812–830.e814. 10.1016/j.immuni.2018.03.023.29628290
Chandra, SA; Nolan, MW; Malarkey, DE. (2010). Chemical carcinogenesis of the gastrointestinal tract in rodents: an overview with emphasis on NTP carcinogenesis bioassays [Review]. Toxicol Pathol 38: 188–197. 10.1177/0192623309356452.20019352
Chappell, GA; Wolf, JC; Thompson, CM. (2022). Crypt and villus transcriptomic responses in mouse small intestine following oral exposure to hexavalent chromium. Toxicol Sci 186: 43–57. 10.1093/toxsci/kfab152.34935971
Chatterjee, N; Walker, GC. (2017). Mechanisms of DNA damage, repair, and mutagenesis [Review]. Environ Mol Mutagen 58: 235–263. 10.1002/em.22087.28485537
Chebeir, M; Liu, H. (2016). Kinetics and mechanisms of Cr(VI) formation via the oxidation of Cr(III) solid phases by chlorine in drinking water. Environ Sci Technol 50: 701–710. 10.1021/acs.est.5b05739.26647114
Chen, Q; Li, H; Chen, W; Yao, W; Li, S; Xu, Y; Meng, A. (1997). [Impact of chromium compounds on female reproductive function]. Gongye Weisheng yu Zhiyebin 23: 180–182.
Chen, QY; Murphy, A; Sun, H; Costa, M. (2019). Molecular and epigenetic mechanisms of Cr(VI)-induced carcinogenesis [Review]. Toxicol Appl Pharmacol 377: 114636. 10.1016/j.taap.2019.114636.31228494
Cheng, L; Liu, S; Dixon, K. (1998). Analysis of repair and mutagenesis of chromium-induced DNA damage in yeast, mammalian cells, and transgenic mice. Environ Health Perspect 106: 1027–1032.9703488
Cheng, L; Sonntag, DM; de Boer, J; Dixon, K. (2000). Chromium(VI)-induced mutagenesis in the lungs of big blue transgenic mice. J Environ Pathol Toxicol Oncol 19: 239–249.10983890
Chiba, T; Marusawa, H; Ushijima, T. (2012). Inflammation-associated cancer development in digestive organs: mechanisms and roles for genetic and epigenetic modulation [Review]. Gastroenterology 143: 550–563. 10.1053/j.gastro.2012.07.009.22796521
Chopra, A; Pereira, G; Gomes, T; Pereira, J; Prabhu, P; Krishnan, S; Rao, CV. (1996). A study of chromium and ethanol toxicity in female Wistar rats. Toxicol Environ Chem 53: 91–106. 10.1080/02772249609358274.
Chowdhury, AR; Mitra, C. (1995). Spermatogenic and steroidogenic impairment after chromium treatment in rats. Indian J Exp Biol 33: 480–484.7590955
Christensen, MM; Ernst, E; Ellermann-Eriksen, S. (1992). Cytotoxic effects of hexavalent chromium in cultured murine macrophages. Arch Toxicol 66: 347–353.1376984
Christensen, OB; Christensen, MB; Maibach, HI. (1984). Flare-up reactions and desensitization from oral dosing in chromate-sensitive guinea pigs. Contact Derm 10: 277–279.
Christiansen, PM. (1968). The incidence of achlorhydria and hypochlorhydria in healthy subjects and patients with gastrointestinal diseases. Scand J Gastroenterol 3: 497–508. 10.3109/00365526809179909.5706664
Chuang, SM; Liou, GY; Yang, JL. (2000). Activation of JNK, p38 and ERK mitogen-activated protein kinases by chromium(VI) is mediated through oxidative stress but does not affect cytotoxicity. Carcinogenesis 21: 1491–1500.10910949
Cid, MG; Loria, D; Vilensky, M; Miotti, JL; Matos, E. (1991). Leather tanning workers: chromosomal aberrations in peripheral lymphocytes and micronuclei in exfoliated cells in urine. Mutat Res 259: 197–201. 10.1016/0165-1218(91)90053-O.1994245
Cieślak-Golonka, M. (1996). Toxic and mutagenic effects of chromium(VI). A review. Polyhedron 15: 3667–3689. 10.1016/0277-5387(96)00141-6.
Ciminera, P; Superior, MJ; Bullman, T. (2016). Findings from the Department of Veterans Affairs Qarmat Ali Medical Surveillance Program. Mil Med 181: 307–310. 10.7205/MILMED-D-15-00278.27046175
Clementino, M; Kim, D; Zhang, Z. (2019). Constitutive Activation of NAD-Dependent Sirtuin 3 Plays an Important Role in Tumorigenesis of Chromium(VI)-Transformed Cells. Toxicol Sci 169: 224–234. 10.1093/toxsci/kfz032.30715550
Coelho, P; García-Lestón, J; Costa, S; Costa, C; Silva, S; Dall'Armi, V; Zoffoli, R; Bonassi, S; de Lima, JP; Gaspar, JF; Pásaro, E; Laffon, B; Teixeira, JP. (2013). Genotoxic effect of exposure to metal(loid)s. A molecular epidemiology survey of populations living and working in Panasqueira mine area, Portugal. Environ Int 60: 163–170. 10.1016/j.envint.2013.08.014.24036326
Coffing, S; Engel, M; Dickinson, D; Thiffeault, C; Spellman, R; Shutsky, T; Schuler, M. (2011). The rat gut micronucleus assay: a good choice for alternative in vivo genetic toxicology testing strategies. Environ Mol Mutagen 52: 269–279. 10.1002/em.20616.20872852
Cohen, MD; Prophete, C; Sisco, M; Chen, LC; Zelikoff, JT; Smee, JJ; Holder, AA; Crans, DC. (2006). Pulmonary immunotoxic potentials of metals are governed by select physicochemical properties: chromium agents. J Immunotoxicol 3: 69–81. 10.1080/15476910600718434.18958687
Cohen, MD; Sisco, M; Baker, K; Bowser, D; Chen, LC; Schlesinger, RB. (2003). Impact of coexposure to ozone on the carcinogenic potential of inhaled chromium. 1. Effects on retention and on extra- and intracellular distribution. J Toxicol Environ Health A 66: 39–55. 10.1080/15287390306459.12587290
Cohen, MD; Sisco, M; Prophete, C; Yoshida, K; Chen, LC; Zelikoff, JT; Smee, J; Holder, AA; Stonehuerner, J; Crans, DC; Ghio, AJ. (2010). Effects of metal compounds with distinct physicochemical properties on iron homeostasis and antibacterial activity in the lungs: Chromium and vanadium. Inhal Toxicol 22: 169–178. 10.3109/08958370903161232.19757987
Cohen, MD; Zelikoff, JT; Chen, LC; Schlesinger, RB. (1998). Immunotoxicologic effects of inhaled chromium: role of particle solubility and co-exposure to ozone. Toxicol Appl Pharmacol 152: 30–40. 10.1006/taap.1998.8502.9772197
Cohen, RE; Neiders, ME; Bedi, GS; Comeau, R. (1993). Induction of type 2 cystatin in rat submandibular glands by systemically administered agents. Arch Oral Biol 38: 319–325.7686006
Cohen, SR; Davis, DM; Kramkowski, RS. (1974). Clinical manifestations of chromic acid toxicity: Nasal lesions in electroplate workers. Cutis 13: 558–568.
Cohen, SR; Kramkowski, RS. (1973). Health hazard evaluation/toxicity determination. Marsh Plating Corporation, Ypsilanti, Michigan. (HHE-72–118-104). Cincinnati, OH: National Institute for Occupational Safety and Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB232740.
Cole, P; Rodu, B. (2005). Epidemiologic studies of chrome and cancer mortality: a series of meta-analyses. Regul Toxicol Pharmacol 43: 225–231. 10.1016/j.yrtph.2005.06.009.16099572
Collins, BJ; Stout, MD; Levine, KE; Kissling, GE; Melnick, RL; Fennell, TR; Walden, R; Abdo, K; Pritchard, JB; Fernando, RA; Burka, LT; Hooth, MJ. (2010). Exposure to hexavalent chromium resulted in significantly higher tissue chromium burden compared with trivalent chromium following similar oral doses to male F344/N rats and female B6C3F1 mice. Toxicol Sci 118: 368–379. 10.1093/toxsci/kfq263.20843897
Costa, M; Zhitkovich, A; Toniolo, P. (1993). DNA-protein cross-links in welders: molecular implications. Cancer Res 53: 460–463.8425177
Cotton, FA; Wilkinson, G; Murillo, CA; Bochmann, M. (1999). The elements of the first transition series. In Advanced Inorganic Chemistry. New York: Wiley.
Cox, DR. (1972). Regression models and life-tables. J R Stat Soc Ser B 34: 187–220.
Creasy, DM; Chapin, RE. (2018). Chapter 17 - Male reproductive system. In Fundamentals of Toxicologic Pathology (Third Edition). London, UK: Academic Press of Elsevier. 10.1016/B978-0-12-809841-7.00017-4.
Crew, KD; Neugut, AI. (2004). Epidemiology of upper gastrointestinal malignancies. Semin Oncol 31: 450–464. 10.1053/j.seminoncol.2004.04.021.15297938
Crissman, JW; Goodman, DG; Hildebrandt, PK; Maronpot, RR; Prater, DA; Riley, JH; Seaman, WJ; Thake, DC. (2004). Best practices guideline: Toxicologic histopathology. Toxicol Pathol 32: 126–131. 10.1080/01926230490268756.14713558
Cullen, JM; Ward, JM; Thompson, CM. (2015). Reevaluation and Classification of Duodenal Lesions in B6C3F1 Mice and F344 Rats from 4 Studies of Hexavalent Chromium in Drinking Water. Toxicol Pathol 44: 279–289. 10.1177/0192623315611501.26538584
Cummings, DE; Fendorf, S; Singh, N; Sani, RK; Peyton, BM; Magnuson, TS. (2007). Reduction of Cr(VI) under acidic conditions by the facultative Fe(lll)-reducing bacterium Acidiphilium cryptum. Environ Sci Technol 41: 146–152. 10.1021/es061333k.17265940
Cussler, EL. (1999). Diffusion: Mass transfer in fluid systems (2nd ed.). Cambridge, UK: Cambridge University Press.
D'Agostini, F; Izzotti, A; Bennicelli, C; Camoirano, A; Tampa, E; De Flora, S. (2002). Induction of apoptosis in the lung but not in the liver of rats receiving intra-tracheal instillations of chromium(VI). Carcinogenesis 23: 587–593. 10.1093/carcin/23.4.587.11960910
Dai, J; Ji, Y; Wang, W; Kim, D; Fai, LY; Wang, L; Luo, J; Zhang, Z. (2017a). Loss of fructose-1,6-bisphosphatase induces glycolysis and promotes apoptosis resistance of cancer stem-like cells: An important role in hexavalent chromium-induced carcinogenesis. Toxicol Appl Pharmacol 331: 164–173. 10.1016/j.taap.2017.06.014.28624442
Dai, L; Xu, W; Li, H; Frank, JA; He, C; Zhang, Z; Chen, G. (2017b). Effects of hexavalent chromium on mouse splenic T lymphocytes. Toxicol In Vitro 45: 166–171. 10.1016/j.tiv.2017.09.006.28899767
Dana Devi, K; Rozati, R; Saleha Banu, B; Jamil, K; Grover, P. (2001). In vivo genotoxic effect of potassium dichromate in mice leukocytes using comet assay. Food Chem Toxicol 39: 859–865.11434993
Danadevi, K; Rozati, R; Banu, BS; Grover, P. (2004). Genotoxic evaluation of welders occupationally exposed to chromium and nickel using the Comet and micronucleus assays. Mutagenesis 19: 35–41. 10.1093/mutage/geh001.14681311
Danadevi, K; Rozati, R; Reddy, PP; Grover, P. (2003). Semen quality of Indian welders occupationally exposed to nickel and chromium. Reprod Toxicol 17: 451–456.12849857
Das, J; Kang, MH; Kim, E; Kwon, DN; Choi, YJ; Kim, JH. (2015). Hexavalent chromium induces apoptosis in male somatic and spermatogonial stem cells via redox imbalance. Sci Rep 5: 13921. 10.1038/srep13921.26355036
Davidson, T; Kluz, T; Burns, F; Rossman, T; Zhang, Q; Uddin, A; Nadas, A; Costa, M. (2004). Exposure to chromium (VI) in the drinking water increases susceptibility to UV-induced skin tumors in hairless mice. Toxicol Appl Pharmacol 196: 431–437. 10.1016/j.taap.2004.01.006.15094314
Day, CP; James, OF. (1998). Hepatic steatosis: Innocent bystander or guilty party? [Review]. Hepatology 27: 1463–1466. 10.1002/hep.510270601.9620314
De Boeck, K. (2020). Cystic fibrosis in the year 2020: A disease with a new face [Review]. Acta Paediatr 109: 893–899. 10.1111/apa.15155.31899933
De Flora, S; Badolati, GS; Serra, D; Picciotto, A; Magnolia, MR; Savarino, V. (1987a). Circadian reduction of chromium in the gastric environment. Mutat Res Lett 192: 169–174. 10.1016/0165-7992(87)90051-0.
De Flora, S; Bagnasco, M; Serra, D; Zanacchi, P. (1990). Genotoxicity of chromium compounds. A review [Review]. Mutat Res Rev Genet Toxicol 238: 99–172. 10.1016/0165-1110(90)90007-X.
De Flora, S; Camoirano, A; Bagnasco, M; Bennicelli, C; Corbett, GE; Kerger, BD. (1997). Estimates of the chromium(VI) reducing capacity in human body compartments as a mechanism for attenuating its potential toxicity and carcinogenicity. Carcinogenesis 18: 531–537.9067553
De Flora, S; Camoirano, A; Micale, RT; La Maestra, S; Savarino, V; Zentilin, P; Marabotto, E; Suh, M; Proctor, DM. (2016). Reduction of hexavalent chromium by fasted and fed human gastric fluid. I. Chemical reduction and mitigation of mutagenicity. Toxicol Appl Pharmacol 306: 113–119. 10.1016/j.taap.2016.07.004.27404458
De Flora, S; D'Agostini, F; Balansky, R; Micale, R; Baluce, B; Izzotti, A. (2008). Lack of genotoxic effects in hematopoietic and gastrointestinal cells of mice receiving chromium(VI) with the drinking water [Review]. Mutat Res 659: 60–67. 10.1016/j.mrrev.2007.11.005.18155955
De Flora, S; Iltcheva, M; Balansky, RM. (2006). Oral chromium(VI) does not affect the frequency of micronuclei in hematopoietic cells of adult mice and of transplacentally exposed fetuses. Mutat Res 610: 38–47. 10.1016/j.mrgentox.2006.06.011.16872865
De Flora, S; Petruzzelli, S; Camoirano, A; Bennicelli, C; Romano, M; Rindi, M; Ghelarducci, L; Giuntini, C. (1987b). Pulmonary metabolism of mutagens and its relationship with lung cancer and smoking habits. Cancer Res 47: 4740–4745.3621172
De Mattia, G; Bravi, MC; Laurenti, O; De Luca, O; Palmeri, A; Sabatucci, A; Mendico, G; Ghiselli, A. (2004). Impairment of cell and plasma redox state in subjects professionally exposed to chromium. Am J Ind Med 46: 120–125. 10.1002/ajim.20044.15273963
Deloughery, Z; Luczak, MW; Ortega-Atienza, S; Zhitkovich, A. (2015). DNA double-strand breaks by Cr(VI) are targeted to euchromatin and cause ATR-dependent phosphorylation of histone H2AX and its ubiquitination. Toxicol Sci 143: 54–63. 10.1093/toxsci/kfu207.25288669
Delshad, SD; Almario, CV; Chey, WD; Spiegel, BMR. (2020). Pevalence of gastroesophageal reflux disease and proton pump inhibitor-refractory symptoms. Gastroenterology 158: 1250. 10.1053/j.gastro.2019.12.014.31866243
Deng, C; Lee, HH; Xian, H; Yao, M; Huang, J; Ou, B. (1988). Chromosomal aberrations and sister chromatid exchanges of peripheral blood lymphocytes in Chinese electroplating workers: Effect of nickel and chromium. J Trace Elem Exp Med 1: 57–62.
Deng, G; Wu, K; Cruce, AA; Bowman, MK; Vincent, JB. (2015). Binding of trivalent chromium to serum transferrin is sufficiently rapid to be physiologically relevant. J Inorg Biochem 143: 48–55. 10.1016/j.jinorgbio.2014.12.004.25528477
Deng, Y; Wang, M; Tian, T; Lin, S; Xu, P; Zhou, L; Dai, C; Hao, Q; Wu, Y; Zhai, Z; Zhu, Y; Zhuang, G; Dai, Z. (2019). The Effect of Hexavalent Chromium on the Incidence and Mortality of Human Cancers: A Meta-Analysis Based on Published Epidemiological Cohort Studies. 9: 24. 10.3389/fonc.2019.00024.
Dertinger, SD; Torous, DK; Hayashi, M; Macgregor, JT. (2011). Flow cytometric scoring of micronucleated erythrocytes: an efficient platform for assessing in vivo cytogenetic damage [Review]. Mutagenesis 26: 139–145. 10.1093/mutage/geq055.21164195
Devoy, J; Géhin, A; Müller, S; Melczer, M; Remy, A; Antoine, G; Sponne, I. (2016). Evaluation of chromium in red blood cells as an indicator of exposure to hexavalent chromium: An in vitro study. Toxicol Lett 255: 63–70. 10.1016/j.toxlet.2016.05.008.27178267
Djelloul, S; Forgue-Lafitte, ME; Hermelin, B; Mareel, M; Bruyneel, E; Baldi, A; Giordano, A; Chastre, E; Gespach, C. (1997). Enterocyte differentiation is compatible with SV40 large T expression and loss of p53 function in human colonic Caco-2 cells. Status of the pRb1 and pRb2 tumor suppressor gene products. FEBS Lett 406: 234–242. 10.1016/s0014-5793(97)00208-1.9136893
Dobrovolsky, VN; Heflich, RH. (2018). Chapter eleven: Detecting mutations in vivo. In Mutagenicity: Assays and applications. Cambridge, MA: Academic Press. 10.1016/B978-0-12-809252-1.00011-0.
Doki, K; Darwich, AS; Patel, N; Rostami-Hodjegan, A. (2017). Virtual bioequivalence for achlorhydric subjects: The use of PBPK modelling to assess the formulation-dependent effect of achlorhydria. Eur J Pharm Sci 109. 10.1016/j.ejps.2017.07.035.
Donaldson, RM, Jr; Barreras, RF. (1966). Intestinal absorption of trace quantities of chromium. J Lab Clin Med 68: 484–493.5922758
Dornan, JD. (1981). Occupational dermatoses amongst chrome platers in the Sheffield area 1977--80. Contact Derm 7: 354–355. 10.1111/j.1600-0536.1981.tb04116.x.
Downs, BW; Sauder, HM. (2023). Septal perforation. In StatPearls. Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK537208/.
Dressman, JB; Berardi, RR; Dermentzoglou, LC; Russell, TL; Schmaltz, SP; Barnett, JL; Jarvenpaa, KM. (1990). Upper gastrointestinal (GI) pH in young, healthy men and women. Pharm Res 7: 756–761.2395805
Eastmond, DA. (2014). Sister chromatid exchanges [Encyclopedia]. In P Wexler (Ed.), Encyclopedia of toxicology: Volume 4 (3rd ed., pp. 276–277). Cambridge, MA: Academic Press. 10.1016/B978-0-12-386454-3.00062-2.
Eastmond, DA; Hartwig, A; Anderson, D; Anwar, WA; Cimino, MC; Dobrev, I; Douglas, GR; Nohmi, T; Phillips, DH; Vickers, C. (2009). Mutagenicity testing for chemical risk assessment: Update of the WHO/IPCS harmonized scheme. Mutagenesis 24: 341–349. 10.1093/mutage/gep014.19535363
Eastmond, DA; MacGregor, JT; Slesinski, RS. (2008). Trivalent chromium: Assessing the genotoxic risk of an essential trace element and widely used human and animal nutritional supplement. Crit Rev Toxicol 38: 173–190. 10.1080/10408440701845401.18324515
Eferl, R; Wagner, EF. (2003). AP-1: a double-edged sword in tumorigenesis [Review]. Nat Rev Cancer 3: 859–868. 10.1038/nrc1209.14668816
EFSA CONTAM Panel (EFSA Panel on Contaminants in the Food Chain). (2014). Scientific Opinion on the risks to public health related to the presence of chromium in food and drinking water. EFSA J 12: 3595. 10.2903/j.efsa.2014.3595.
Egger, M; Smith, GD; Schneider, M; Minder, C. (1997). Bias in meta-analysis detected by a simple, graphical test. Br Med J 315: 629–634. 10.1136/bmj.315.7109.629.9310563
Eizaguirre-García, D; Rodríguez-Andrés, C; Watt, G. (2000). Congenital anomalies in Glasgow between 1982 and 1989 and chromium waste. J Public Health (Oxf) 22: 54–58. 10.1093/pubmed/22.1.54.
El-Demerdash, FM; Jebur, AB; Nasr, HM; Hamid, HM. (2019). Modulatory effect of Turnera diffusa against testicular toxicity induced by fenitrothion and/or hexavalent chromium in rats. Environ Toxicol 34: 330–339. 10.1002/tox.22688.30578656
El-Demerdash, FM; Yousef, MI; Elaswad, FA. (2006). Biochemical study on the protective role of folic acid in rabbits treated with chromium (VI). J Environ Sci Health B 41: 731–746. 10.1080/03601230600704282.16785179
El Safty, AMK; Samir, AM; Mekkawy, MK; Fouad, MM. (2018). Genotoxic effects due to exposure to chromium and nickel among electroplating workers. Int J Toxicol 37: 234–240. 10.1177/1091581818764084.29554825
Elbetieha, A; Al-Hamood, MH. (1997). Long-term exposure of male and female mice to trivalent and hexavalent chromium compounds: effect on fertility. Toxicology 116: 39–47. 10.1016/S0300-483X-(96)03516-0.9020505
Elhosary, N; Maklad, A; Soliman, E; El-Ashmawy, N; Oreby, M. (2014). Evaluation of oxidative stress and DNA damage in cement and tannery workers in Egypt. Inhal Toxicol 26: 289–298. 10.3109/08958378.2014.885100.24617565
Elsaieed, EM; Nada, SA. (2002). Teratogenicity of hexavalent chromium in rats and the beneficial role of ginseng. Bull Environ Contam Toxicol 68: 361–368. 10.1007/s00128-001-0262-0.11993810
Elshazly, MO; Morgan, AM; Ali, ME; Abdel-Mawla, E; Abd El-Rahman, SS. (2016). The mitigative effect of Raphanus sativus oil on chromium-induced geno- and hepatotoxicity in male rats. JAR 7: 413–421. 10.1016/j.jare.2016.02.008.27222746
EMEA (European Medicines Agency). (2008). Non-clinical guideline on drug induced hepatotoxicity. (EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003355.pdf.
EMEA (European Medicines Agency). (2010). Reflection paper on non-clinical evaluation of drug-induced liver injury (DILI). (EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2010/07/WC500094591.pdf.
Engström, G; Hedblad, B; Berglund, G; Janzon, L; Lindgärde, F. (2007a). Plasma levels of complement C3 is associated with development of hypertension: a longitudinal cohort study. J Hum Hypertens 21: 276–282. 10.1038/sj.jhh.1002129.17167524
Engström, G; Hedblad, B; Eriksson, KF; Janzon, L; Lindgärde, F. (2005). Complement C3 is a risk factor for the development of diabetes: a population-based cohort study. Diabetes 54: 570–575. 10.2337/diabetes.54.2.570.15677517
Engström, G; Hedblad, B; Janzon, L; Lindgärde, F. (2007b). Complement C3 and C4 in plasma and incidence of myocardial infarction and stroke: a population-based cohort study. Eur J Cardiovasc Prev Rehabil 14: 392–397. 10.1097/01.hjr.0000244582.30421.b2.17568238
Evans, TJ; Ganjam, VK. (2011). Chapter 2 - Reproductive anatomy and physiology. In RC Gupta (Ed.), Reproductive and Developmental Toxicology (1st ed., pp. 7–32). San Diego, CA: Academic Press. 10.1016/B978-0-12-382032-7.10002-5.
Ewis, AA; Kondo, K; Dang, F; Nakahori, Y; Shinohara, Y; Ishikawa, M; Baba, Y. (2006). Surfactant protein B gene variations and susceptibility to lung cancer in chromate workers. Am J Ind Med 49: 367–373. 10.1002/ajim.20283.16570259
Fagliano, JA; Savrin, J; Udasin, I; Gochfeld, M. (1997). Community exposure and medical screening near chromium waste sites in New Jersey. Regul Toxicol Pharmacol 26: S13–S22. 10.1006/rtph.1997.1134.9380833
Faux, SP; Gao, M; Aw, TC; Braithwaite, RA; Levy, LS. (1994). Molecular epidemiological studies in workers exposed to chromium-containing compounds. Clin Chem 40: 1454–1456.
Faye, AS; Holmer, AK; Axelrad, JE. (2022). Cancer in inflammatory bowel disease. Gastroenterol Clin North Am 51: 649–666. 10.1016/j.gtc.2022.05.003.36153115
Fébel, H; Szegedi, B; Huszár, S. (2001). Absorption of inorganic, trivalent and hexavalent chromium following oral and intrajejunal doses in rats. Acta Vet Hung 49: 203–209.11402649
Feldman, M; Barnett, C. (1991). Fasting gastric pH and its relationship to true hypochlorhydria in humans. Dig Dis Sci 36: 866–869. 10.1007/BF01297133.2070698
Fendorf, S; Wielinga, BW; Hansel, CM. (2000). Chromium transformations in natural environments: The role of biological and abiological. processes in chromium(VI) reduction. International Geology Review 42: 691–701. 10.1080/00206810009465107.
Fendorf, SE. (1995). Surface reactions of chromium in soils and waters. Geoderma 67: 55–71. 10.1016/0016-7061(94)00062-F.
Fendorf, SE; Li, G. (1996). Kinetics of Chromate Reduction by Ferrous Iron. Environ Sci Technol 30: 1614–1617. 10.1021/es950618m.
Fernandes, MA; Mota, IM; Silva, MT; Oliveira, CR; Geraldes, CF; Alpoim, MC. (1999). Human erythrocytes are protected against chromate-induced peroxidation. Ecotoxicol Environ Saf 43: 38–46. 10.1006/eesa.1998.1755.10330319
Fernández-Nieto, M; Quirce, S; Carnés, J; Sastre, J. (2006). Occupational asthma due to chromium and nickel salts. Int Arch Occup Environ Health 79: 483–486. 10.1007/s00420-005-0078-z.16402272
Ferron, GA; Upadhyay, S; Zimmermann, R; Karg, E. (2013). Model of the deposition of aerosol particles in the respiratory tract of the rat. II. Hygroscopic particle deposition. J Aerosol Med Pulm Drug Deliv 26: 101–119. 10.1089/jamp.2011.0965.23550602
Figgitt, M; Newson, R; Leslie, IJ; Fisher, J; Ingham, E; Case, CP. (2010). The genotoxicity of physiological concentrations of chromium (Cr(III) and Cr(VI)) and cobalt (Co(II)): an in vitro study. Mutat Res 688: 53–61. 10.1016/j.mrfmmm.2010.03.008.20227425
Figoni, RA; Treagan, L. (1975). Inhibitory effect of nickel and chromium upon antibody response of rats to immunization with T-1 phage. Res Commun Mol Pathol Pharmacol 11: 335–338.
Figueiredo, ACM, G; Gomes-Filho, IS; Silva, RB; Pereira, PPS; Mata, FAF, D; Lyrio, AO; Souza, ES; Cruz, SS; Pereira, MG. (2018). Maternal anemia and low birth weight: A systematic review and meta-analysis [Review]. Nutrients 10: 601. 10.3390/nu10050601.29757207
Finley, BL; Kerger, BD; Katona, MW; Gargas, ML; Corbett, GC; Paustenbach, DJ. (1997). Human ingestion of chromium (VI) in drinking water: pharmacokinetics following repeated exposure. Toxicol Appl Pharmacol 142: 151–159. 10.1006/taap.1996.7993.9007044
Floro, NA; Wetterhahn, KE. (1984). Effect of chromium(III) on poly(dG-dC) conformation. Biochem Biophys Res Commun 124: 106–113. 10.1016/0006-291x(84)90923-9.6497874
Foley, GL. (2001). Overview of male reproductive pathology [Review]. Toxicol Pathol 29: 49–63. 10.1080/019262301301418856.11215684
Foster, P; Gray, LE, Jr. (2013). Toxic responses of the reproductive system. In CD Klaassen (Ed.), Casarett & Doull's toxicology: The basic science of poisons (8th ed., pp. 861–906). New York, NY: McGraw-Hill Education. https://www.mheducation.com/highered/product/casarett-doull-s-toxicology-basic-science-poisons-9th-edition-klaassen/9781259863745.html.
Fowler, B; Sexton, M. (2015). Handbook on the toxicology of metals. In GF Nordberg; BA Fowler; M Nordberg (Eds.), HANDBOOK ON THE TOXICOLOGY OF METALS, VOL I & II, 4TH EDITION (4th ed., pp. 787–797). Burlington, MA: Elsevier Science. 10.1016/C2011-0-07884-5.
Fox, JG; Wang, TC. (2007). Inflammation, atrophy, and gastric cancer [Review]. J Clin Invest 117: 60–69. 10.1172/JCI30111.17200707
Fox, JG; Wang, TC. (2014). Dietary factors modulate Helicobacter-associated gastric cancer in rodent models. Toxicol Pathol 42: 162–181. 10.1177/0192623313512564.24301796
Francke, S; Mog, S. (2021). Pathology review of hexavalent chromium mode of action evidence. U.S. Department of Health and Human Services, Food and Drug Administration.
Fresquez, MR; Pappas, RS; Watson, CH. (2013). Establishment of toxic metal reference range in tobacco from US cigarettes. J Anal Toxicol 37: 298–304. 10.1093/jat/bkt021.23548667
Frey, M; Seidel, C; Edwards, M. (2004). Occurrence survey of boron and hexavalent chromium. (No. 91044F). Denver, CO: American Water Works Association Research Foundation. http://www.waterrf.org/PublicReportLibrary/91044F.pdf.
Fryzek, JP; Mumma, MT; Mclaughlin, JK; Henderson, BE; Blot, WJ. (2001). Cancer mortality in relation to environmental chromium exposure. J Occup Environ Med 43: 635–640.11464395
Furman, D; Campisi, J; Verdin, E; Carrera-Bastos, P; Targ, S; Franceschi, C; Ferrucci, L; Gilroy, DW; Fasano, A; Miller, GW; Miller, AH; Mantovani, A; Weyand, CM; Barzilai, N; Goronzy, JJ; Rando, TA; Effros, RB; Lucia, A; Kleinstreuer, N; Slavich, GM. (2019). Chronic inflammation in the etiology of disease across the life span. Nat Med 25: 1822–1832. 10.1038/s41591-019-0675-0.31806905
Gabay, M; Li, Y; Felsher, DW. (2014). MYC activation is a hallmark of cancer initiation and maintenance [Review]. Cold Spring Harb Perspect Med 4. 10.1101/cshperspect.a014241.
Gambelunghe, A; Piccinini, R; Abbritti, G; Ambrogi, M; Ugolini, B; Marchetti, C; Migliorati, G; Balducci, C; Muzi, G. (2006). Chromium VI-induced apoptosis in a human bronchial epithelial cell line (BEAS-2B) and a lymphoblastic leukemia cell line (MOLT-4). J Occup Environ Med 48: 319–325. 10.1097/01.jom.0000197859.46894.7d.16531837
Gambelunghe, A; Piccinini, R; Ambrogi, M; Villarini, M; Moretti, M; Marchetti, C; Abbritti, G; Muzi, G. (2003). Primary DNA damage in chrome-plating workers. Toxicology 188: 187–195.12767690
Gandhi, M; Aweeka, F; Greenblatt, RM; Blaschke, TF. (2004). Sex differences in pharmacokinetics and pharmacodynamics [Review]. Annu Rev Pharmacol Toxicol 44: 499–523. 10.1146/annurev.pharmtox.44.101802.121453.14744256
Gao, M; Binks, SP; Chipman, JK; Levy, LS; Braithwaite, RA; Brown, SS. (1992). Induction of DNA strand breaks in peripheral lymphocytes by soluble chromium compounds. Hum Exp Toxicol 11: 77–82. 10.1177/096032719201100203.1349223
Gao, M; Levy, LS; Faux, SP; Aw, TC; Braithwaite, RA; Brown, SS. (1994). Use of molecular epidemiological techniques in a pilot study on workers exposed to chromium. Occup Environ Med 51: 663–668. 10.1136/oem.51.10.663.8000490
Gatto, NM; Kelsh, MA; Mai, DH; Suh, M; Proctor, DM. (2010). Occupational exposure to hexavalent chromium and cancers of the gastrointestinal tract: a meta-analysis. Cancer Detect Prev 34: 388–399. 10.1016/j.canep.2010.03.013.
Gazon, H; Barbeau, B; Mesnard, JM; Peloponese, JM. (2017). Hijacking of the AP-1 Signaling Pathway during Development of ATL [Review]. FMICB 8: 2686. 10.3389/fmicb.2017.02686.29379481
GBD 2017 (GBD 2017 Gastro-oesophageal Reflux Disease Collaborators). (2020). The global, regional, and national burden of gastro-oesophageal reflux disease in 195 countries and territories, 1990–2017:Aa systematic analysis for the Global Burden of Disease Study 2017. Lancet Gastroenterology and Hepatology 5: 561–581. 10.1016/S2468-1253(19)30408-X.32178772
Ge, H; Li, Z; Jiang, L; Li, Q; Geng, C; Yao, X; Shi, X; Liu, Y; Cao, J. (2019). Cr (VI) induces crosstalk between apoptosis and autophagy through endoplasmic reticulum stress in A549 cells. Chem Biol Interact 298: 35–42. 10.1016/j.cbi.2018.10.024.30416085
Geetha, S; Sai Ram, M; Mongia, SS; Singh, V; Ilavazhagan, G; Sawhney, RC. (2003). Evaluation of antioxidant activity of leaf extract of Seabuckthorn (Hippophae rhamnoides L.) on chromium(VI) induced oxidative stress in albino rats. J Ethnopharmacol 87: 247–251. 10.1016/S0378-8741(03)00154-5.12860317
Gehlhaus, MW, III; Gift, JS; Hogan, KA; Kopylev, L; Schlosser, PM; Kadry, AR. (2011). Approaches to cancer assessment in EPA's Integrated Risk Information System [Review]. Toxicol Appl Pharmacol 254: 170–180. 10.1016/j.taap.2010.10.019.21034767
Gelberg, H. (2018). Pathophysiological mechanisms of gastrointestinal toxicity. In CA McQueen (Ed.), Comprehensive toxicology, vol 3 (3rd ed., pp. 139–178). Amsterdam, Netherlands: Elsevier. 10.1016/B978-0-12-801238-3.10923-7.
Geoffroy-Siraudin, C; Perrard, MH; Chaspoul, F; Lanteaume, A; Gallice, P; Durand, P; Guichaoua, MR. (2010). Validation of a rat seminiferous tubule culture model as a suitable system for studying toxicant impact on meiosis effect of hexavalent chromium. Toxicol Sci 116: 286–296. 10.1093/toxsci/kfq099.20360146
Georgieva, AV; Kimbell, JS; Schlosser, PM. (2003). A distributed-parameter model for formaldehyde uptake and disposition in the rat nasal lining. Inhal Toxicol 15: 1435–1463. 10.1080/08958370390249085.14648358
Gerin, M; Fletcher, AC; Gray, C; Winkelmann, R; Boffetta, P; Simonato, L. (1993). Development and use of a welding process exposure matrix in a historical prospective study of lung cancer risk in European welders. Int J Epidemiol 22: S22–S28.8132388
Gibb, H; Wang, J; OĽeary, K; Chen, C; Bateson, TF; Kopylev, L. (2020). The effect of age on the relative risk of lung cancer mortality in a cohort of chromium production workers. Am J Ind Med 63: 774–778. 10.1002/ajim.23152.32687217
Gibb, HJ; Lees, PS; Pinsky, PF; Rooney, BC. (2000a). Clinical findings of irritation among chromium chemical production workers. Am J Ind Med 38: 127–131.10893505
Gibb, HJ; Lees, PS; Pinsky, PF; Rooney, BC. (2000b). Lung cancer among workers in chromium chemical production. Am J Ind Med 38: 115–126.10893504
Gibb, HJ; Lees, PS; Wang, J; Grace OĽeary, K. (2015). Extended followup of a cohort of chromium production workers. Am J Ind Med 58: 905–913. 10.1002/ajim.22479.26041683
Glaser, U; Hochrainer, D; Klöeppel, H; Kuhnen, H. (1985). Low level chromium (VI) inhalation effects on alveolar macrophages and immune functions in Wistar rats. Arch Toxicol 57: 250–256. 10.1007/BF00324787.3879166
Glaser, U; Hochrainer, D; Kloeppel, H; Oldiges, H. (1986). Carcinogenicity of sodium dichromate and chromium (VI/III)oxide aerosols inhaled by male Wistar rats. Toxicology 42: 219–232. 10.1016/0300-483X(86)90011-9.3798470
Glaser, U; Hochrainer, D; Steinhoff, D. (1990). Investigation of irritating properties of inhaled Cr(VI) with possible influence on its carcinogenic action. In NH Seemayer; W Hadnagy (Eds.), Environmental hygiene II (pp. 239–245). Berlin, Germany: Springer-Verlag.
Glaviano, A; Nayak, V; Cabuy, E; Baird, DM; Yin, Z; Newson, R; Ladon, D; Rubio, MA; Slijepcevic, P; Lyng, F; Mothersill, C; Case, CP. (2006). Effects of hTERT on metal ion-induced genomic instability. Oncogene 25: 3424–3435. 10.1038/sj.onc.1209399.16449970
Go'ldina, IR; Saĭchenko, SP; Nadeenko, VG; Diachenko, OZ. (1989). [Changes in the occurrence of sister chromatid exchange and chromosome aberrations in bone marrow cells of mice after administration of chromium with drinking water]. Gig Sanit 7–9.
Gochfeld, M. (2007). Framework for gender differences in human and animal toxicology [Review]. Environ Res 104: 4–21. 10.1016/j.envres.2005.12.005.16616135
Goldberg, MT; Blakey, DH; Bruce, WR. (1983). Comparison of the effects of 1,2-dimethylhydrazine and cyclophosphamide on micronucleus incidence in bone marrow and colon. Mutat Res Fundam Mol Mech Mutagen 109: 91–98. 10.1016/0027-5107(83)90098-2.
Gomes, ER. (1972). Incidence of chromium-induced lesions among electroplating workers in Brazil. Ind Med Surg 41: 21–25.
Gonda, TA; Tu, SP; Wang, TC. (2009). Chronic inflammation, the tumor microenvironment and carcinogenesis [Review]. Cell Cycle 8: 2005–2013. 10.4161/cc.8.13.8985.19550141
Goulart, M; Batoréu, MC; Rodrigues, AS; Laires, A; Rueff, J. (2005). Lipoperoxidation products and thiol antioxidants in chromium exposed workers. Mutagenesis 20: 311–315. 10.1093/mutage/gei043.15985443
Goullé, JP; Saussereau, E; Grosjean, J; Doche, C; Mahieu, L; Thouret, JM; Guerbet, M; Lacroix, C. (2012). Accidental potassium dichromate poisoning. Toxicokinetics of chromium by ICP-MS-CRC in biological fluids and in hair. Forensic Sci Int 217: e8–12. 10.1016/j.forsciint.2011.10.020.22024652
Gray, SJ; Sterling, K. (1950). The tagging of red cells and plasma proteins with radioactive chromium. J Clin Invest 29: 1604–1613. 10.1172/JCI102403.14794790
Greenspan, LC; Lee, MM. (2018). Endocrine disrupters and pubertal timing [Review]. Curr Opin Endocrinol Diabetes Obes 25: 49–54. 10.1097/MED.0000000000000377.29135489
Gromadzińska, J; Wasowicz, W; Sklodowska, M; Bulikowski, W; Rydzyński, K. (1996). The influence of atmospheric chromium on selenium content and glutathione peroxidase activity in blood of tannery workers. Environ Health Perspect 104: 1312–1316. 10.1289/ehp.104-1469531.9118872
Group, FW. (2000). Nonclincial assessment of potential hepatotoxicity in man (a concept paper meant to provide a framework for discussion at a February 12&13 Workshop. FDA Working Group.
Güerci, A; Seoane, A; Dulout, FN. (2000). Aneugenic effects of some metal compounds assessed by chromosome counting in MRC-5 human cells. Mutat Res 469: 35–40.10946240
Guo, X; Feng, L; Lemos, B; Lou, J. (2019). DNA methylation modifications induced by hexavalent chromium. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 37: 133–145. 10.1080/10590501.2019.1592640.31084241
Guo, YJ; Pan, WW; Liu, SB; Shen, ZF; Xu, Y; Hu, LL. (2020). ERK/MAPK signalling pathway and tumorigenesis [Review]. Exp Ther Med 19: 1997–2007. 10.3892/etm.2020.8454.32104259
Guttmann, D; Poage, G; Johnston, T; Zhitkovich, A. (2008). Reduction with glutathione is a weakly mutagenic pathway in chromium(VI) metabolism. Chem Res Toxicol 21: 2188–2194. 10.1021/tx800265g.18808157
Haberland, VMM; Magin, S; Iliakis, G; Hartwig, A. (2023). Impact of Manganese and Chromate on Specific DNA Double-Strand Break Repair Pathways. International Journal of Molecular Sciences 24. 10.3390/ijms241210392.
Halasova, E; Adamkov, M; Matakova, T; Kavcova, E; Poliacek, I; Singliar, A. (2010). Lung cancer incidence and survival in chromium exposed individuals with respect to expression of antiapoptotic protein survivin and tumor suppressor P53 protein. Eur J Med Res 15: 55–59.21147621
Halasova, E; Matakova, T; Musak, L; Polakova, V; Letkova, L; Dobrota, D; Vodicka, P. (2012). Evaluating chromosomal damage in workers exposed to hexavalent chromium and the modulating role of polymorphisms of DNA repair genes. Int Arch Occup Environ Health 85: 473. 10.1007/s00420-011-0684-x.21858514
Halasova, E; Matakova, T; Musak, L; Polakova, V; Vodicka, P. (2008). Chromosomal damage and polymorphisms of DNA repair genes XRCC1 and XRCC3 in workers exposed to chromium. Neuro Endocrinol Lett 29: 658–662.18987609
Halasova, E; Matakova, T; Skerenova, M; Krutakova, M; Slovakova, P; Dzian, A; Javorkova, S; Pec, M; Kypusova, K; Hamzik, J. (2016). Polymorphisms of selected DNA repair genes and lung cancer in chromium exposure. Adv Exp Med Biol 911: 17–22. 10.1007/5584_2016_218.26987333
Hamilton, EM; Young, SD; Bailey, EH; Watts, MJ. (2018). Chromium speciation in foodstuffs: A review [Review]. Food Chem 250. 10.1016/j.foodchem.2018.01.016.
Hanahan, D. (2022). Hallmarks of cancer: New dimensions [Review]. Cancer Discovery 12: 31–46. 10.1158/2159-8290.CD-21-1059.35022204
Hanahan, D; Weinberg, RA. (2011). Hallmarks of cancer: The next generation [Review]. Cell 144: 646–674. 10.1016/j.cell.2011.02.013.21376230
Hanaoka, T; Yamano, Y; Katsuno, N; Kagawa, J; Ishizu, S. (1997). Elevated serum levels of pantropic p53 proteins in chromium workers. Scand J Work Environ Health 23: 37–40. 10.5271/sjweh.176.9098910
Haney, J. (2015a). Consideration of non-linear, non-threshold and threshold approaches for assessing the carcinogenicity of oral exposure to hexavalent chromium. Regul Toxicol Pharmacol 73: 834–852. 10.1016/j.yrtph.2015.10.011.26493004
Haney, J. (2015b). Use of dose-dependent absorption into target tissues to more accurately predict cancer risk at low oral doses of hexavalent chromium. Regul Toxicol Pharmacol 71: 93–100. 10.1016/j.yrtph.2014.11.002.25445295
Hanslian, L; Navratil, J; Jurak, J. (1967). [Damage to the upper respiratory tract by a chromic acid aerosol]. Czech J Occup Med 19: 294–298.
Hantson, P; Van Caenegem, O; Decordier, I; Haufroid, V; Lison, D. (2005). Hexavalent chromium ingestion: Biological markers of nephrotoxicity and genotoxicity. Clin Toxicol 43: 111–112. 10.1081/CLT-50414.
Harris, HH; Levina, A; Dillon, CT; Mulyani, I; Lai, B; Cai, Z; Lay, PA. (2005). Time-dependent uptake, distribution and biotransformation of chromium(VI) in individual and bulk human lung cells: application of synchrotron radiation techniques. J Biol Inorg Chem 10: 105–118. 10.1007/s00775-004-0617-1.15714299
Haschek, WM; Rousseaux, CG; Wallig, MA. (2009). Male reproductive system. In Fundamentals of toxicologic pathology (2nd ed.). Cambridge, MA: Academic Press. 10.1016/B978-0-12-370469-6.00018-0.
Haseman, JK; Bailer, AJ; Kodell, RL; Morris, R; Portier, K. (2001). Statistical issues in the analysis of low-dose endocrine disruptor data. Toxicol Sci 61: 201–210.11353128
Hausladen, DM; Alexander-Ozinskas, A; Mcclain, CN; Fendorf, S. (2018). Hexavalent chromium sources and distribution in California groundwater. Environ Sci Technol 52: 8242–8251. 10.1021/acs.est.7b06627.29949365
Hausladen, DM; Fendorf, S. (2017). Hexavalent chromium generation within naturally structured soils and sediments. Environ Sci Technol 51: 2058–2067. 10.1021/acs.est.6b04039.28084730
Hayakawa, Y; Fox, JG; Gonda, T; Worthley, DL; Muthupalani, S; Wang, TC. (2013). Mouse models of gastric cancer. Cancers 5: 92–130. 10.3390/cancers5010092.24216700
Hayashi, M. (2016). The micronucleus test-most widely used in vivo genotoxicity test [Review]. Genes Environ 38: 18. 10.1186/s41021-016-0044-x.27733885
Hayes, RB; Lilienfeld, AM; Snell, LM. (1979). Mortality in chromium chemical production workers: A prospective study. Int J Epidemiol 8: 365–374. 10.1093/ije/8.4.365.541160
He, F; Ru, X; Wen, T. (2020). NRF2, a transcription factor for stress response and beyond [Review]. International Journal of Molecular Sciences 21: 4777. 10.3390/ijms21134777.32640524
He, J; Qian, X; Carpenter, R; Xu, Q; Wang, L; Qi, Y; Wang, ZX; Liu, LZ; Jiang, BH. (2013). Repression of miR-143 Mediates Cr (VI)-Induced Tumor Angiogenesis via IGF-IR/IRS1/ERK/IL-8 Pathway. Toxicol Sci 134: 26–38. 10.1093/toxsci/kft101.23748240
Hedberg, YS. (2018). Metal allergy: Chromium. In J Chen; J Thyssen (Eds.), Metal allergy (pp. 349–364). Cham, Switzerland: Springer. 10.1007/978-3-319-58503-1_27.
Helmbold, P; Rytter, M; Ziegler, V; Haustein, UF. (1993). Induction of type IV hypersensitivity to contact allergens in guinea pigs by in vitro haptenized allogenic peritoneal exudate cells. Acta Derm Venereol 73: 365–369. 10.2340/0001555573365369.7904404
Henderson, RF. (1984). Use of bronchoalveolar lavage to detect lung damage [Review]. Environ Health Perspect 56: 115–129.6383796
Henderson, RF; Benson, JM; Hahn, FF; Hobbs, CH; Jones, RK; Mauderly, JL; McClellan, RO; Pickrell, JA. (1985). New approaches for the evaluation of pulmonary toxicity: Bronchoalveolar lavage fluid analysis [Review]. Toxicol Sci 5: 451–458.
Hens, B; Brouwers, J; Anneveld, B; Corsetti, M; Symillides, M; Vertzoni, M; Reppas, C; Turner, DB; Augustijns, P. (2014). Gastrointestinal transfer: In vivo evaluation and implementation in in vitro and in silico predictive tools. Eur J Pharm Sci 63: 233–242. 10.1016/j.ejps.2014.07.008.25064697
Hertle, E; van Greevenbroek, MM; Stehouwer, CD. (2012). Complement C3: an emerging risk factor in cardiometabolic disease. Diabetologia 55: 881–884. 10.1007/s00125-012-2462-z.22282163
Hfaiedh, M; Brahmi, D; Zourgui, L. (2014). Protective role of cactus cladodes extract on sodium dichromate-induced testicular injury and oxidative stress in rats. Biol Trace Elem Res 159: 304–311. 10.1007/s12011-014-9969-8.24752970
Hilali, A; Anane, R; Jaaouani, N; Creppy, EE; Verschaeve, L. (2008). Cytogenetic analysis of tannery workers in Morocco. J Appl Toxicol 28: 439–442. 10.1002/jat.1291.17668441
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hiller, MM; Leggett, RW. (2020). A biokinetic model for trivalent or hexavalent chromium in adult humans. J Radiol Prot 40: 19–39. 10.1088/1361-6498/ab4286.31834868
Hinds, W. (1999a). Aerosol science and technology. New York: John Wiley and Sons.
Hinds, WC. (1999b). 11: Respiratory Deposition. In Aerosol Technology: Properties, Behavior, and Measurement ofAirborne Particles (2 ed.). New York, NY: Wiley- Interscience.
Hirose, T; Kondo, K; Takahashi, Y; Ishikura, H; Fujino, H; Tsuyuguchi, M; Hashimoto, M; Yokose, T; Mukai, K; Kodama, T; Monden, Y. (2002). Frequent microsatellite instability in lung cancer from chromate-exposed workers. Mol Carcinog 33: 172–180.11870883
Hjollund, NH; Bonde, JP; Ernst, E; Lindenberg, S; Andersen, AN; Olsen, J. (2005). Spontaneous abortion in IVF couples--a role of male welding exposure. Hum Reprod 20: 1793–1797. 10.1093/humrep/deh680.15760968
Hjollund, NH; Bonde, JP; Hansen, KS. (1995). Male-mediated risk of spontaneous abortion with reference to stainless steel welding. Scand J Work Environ Health 21: 272–276. 10.5271/sjweh.37.8553001
Hjollund, NH; Bonde, JP; Jensen, TK; Ernst, E; Henriksen, TB; Kolstad, HA; Giwercman, A; Skakkebaek, NE; Olsen, J. (1998). Semen quality and sex hormones with reference to metal welding. Reprod Toxicol 12: 91–95.9535501
Hjollund, NH; Bonde, JP; Jensen, TK; Henriksen, TB; Andersson, AM; Kolstad, HA; Ernst, E; Giwercman, A; Skakkebaek, NE; Olsen, J. (2000). Male-mediated spontaneous abortion among spouses of stainless steel welders. Scand J Work Environ Health 26: 187–192.10901109
Hoenig, JM; Heisey, DM. (2001). The abuse of power: The pervasive fallacy of power calculations for data analysis. Am Stat 55: 19–24.
Holmes, AL; Wise, SS; Sandwick, SJ; Lingle, WL; Negron, VC; Thompson, WD; Wise, JP, Sr. (2006). Chronic exposure to lead chromate causes centrosome abnormalities and aneuploidy in human lung cells. Cancer Res 66: 4041–4048. 10.1158/0008-5472.can-05-3312.16618723
Holmes, AL; Wise, SS; Wise, JP. (2008). Carcinogenicity of hexavalent chromium [Review]. Indian J Med Res 128: 353–372.19106434
Hooftman, RN; Arkesteyn, CWM; Roza, P. (1988). Cytotoxicity of some types of welding fume particles to bovine alveolar macrophages. Ann Occup Hyg 32: 95–102. 10.1093/annhyg/32.1.95.3369798
Horiguchi, S; Morinaga, K; Endo, G. (1990). Epidemiological study of mortality from cancer among chromium platers. Asia Pac J Public Health 4: 169–174. 10.1177/101053959000400316.2278768
Houghton, J; Stoicov, C; Nomura, S; Rogers, AB; Carlson, J; Li, H; Cai, X; Fox, JG; Goldenring, JR; Wang, TC. (2004). Gastric cancer originating from bone marrow-derived cells. Science 306: 1568–1571. 10.1126/science.1099513.15567866
Hu, G; Li, P; Cui, X; Li, Y; Zhang, J; Zhai, X; Yu, S; Tang, S; Zhao, Z; Wang, J; Jia, G. (2018). Cr(VI)-induced methylation and down-regulation of DNA repair genes and its association with markers of genetic damage in workers and 16HBE cells. Environ Pollut 238: 833–843. 10.1016/j.envpol.2018.03.046.29627753
Hu, G; Li, P; Li, Y; Wang, T; Gao, X, in; Zhang, W; Jia, G. (2016). Methylation levels of P16 and TP53 that are involved in DNA strand breakage of 16HBE cells treated by hexavalent chromium. Toxicol Lett 249: 15–21. 10.1016/j.toxlet.2016.03.003.27005777
Hu, G; Long, C; Hu, L; Zhang, Y; Hong, S; Zhang, Q; Zheng, P; Su, Z; Xu, J; Wang, L; Gao, X; Zhu, X; Yuan, F; Wang, T; Yu, S; Jia, G. (2022). Blood chromium exposure, immune inflammation and genetic damage: Exploring associations and mediation effects in chromate exposed population. J Hazard Mater 425: 127769. 10.1016/j.jhazmat.2021.127769.34799157
Huang, L; Yu, CH; Hopke, PK; Lioy, PJ; Buckley, BT; Shin, JY; Fan, ZT. (2014). Measurement of soluble and total hexavalent chromium in the ambient airborne particles in New Jersey. Aerosol Air Qual Res 14: 1939–1949. 10.4209/aaqr.2013.10.0312.26120324
Huang, YL; Chen, CY; Sheu, JY; Chuang, IC; Pan, JH; Lin, TH. (1999). Lipid peroxidation in workers exposed to hexavalent chromium. J Toxicol Environ Health A 56: 235–247. 10.1080/009841099158088.10706242
Husgafvel-Pursiainen, K; Kalliomaki, PL; Sorsa, M. (1982). A chromosome study among stainless steel welders. J Occup Environ Med 24: 762–766.
Huvinen, M. (2002) Exposure to chromium and its long-term health effects in stainless steel production. (Doctoral Dissertation). University of Kuopio, Kuopio, Finnland. Retrieved from http://urn.fi/URN:ISBN:951-781-887-4
Huvinen, M; Mäkitie, A; Järventaus, H; Wolff, H; Stjernvall, T; Hovi, A; Hirvonen, A; Ranta, R; Nurminen, M; Norppa, H. (2002a). Nasal cell micronuclei, cytology and clinical symptoms in stainless steel production workers exposed to chromium. Mutagenesis 17: 425–429. 10.1093/mutage/17.5.425.12202631
Huvinen, M; Uitti, J; Oksa, P; Palmroos, P; Laippala, P. (2002b). Respiratory health effects of long-term exposure to different chromium species in stainless steel production. Occup Med (Lond) 52: 203–212.12091586
Huvinen, M; Uitti, J; Zitting, A; Roto, P; Virkola, K; Kuikka, P; Laippala, P; Aitio, A. (1996). Respiratory health of workers exposed to low levels of chromium in stainless steel production. Occup Environ Med 53: 741–747.9038797
Hydrometrics. (2013). Project report background concentrations of inorganic constituents in Montana surface soils. Helena, MT: Hydrometrics, Inc. https://deq.mt.gov/Portals/112/Land/StateSuperfund/Documents/InorganicBackground/BkgdInorganicsReport.pdf.
IARC (International Agency for Research on Cancer). (2012). Arsenic, metals, fibres and dusts. IARC monographs on the evaluation of carcinogenic risks to humans, vol. 100C: A review of human carcinogens [IARC Monograph]. Lyon, France: World Health Organization. http://monographs.iarc.fr/ENG/Monographs/vol100C/mono100C.pdf.
Iarmarcovai, G; Sari-Minodier, I; Chaspoul, F; Botta, C; De Meo, M; Orsiere, T; Berge-Lefranc, JL; Gallice, P; Botta, A. (2005). Risk assessment of welders using analysis of eight metals by ICP-MS in blood and urine and DNA damage evaluation by the comet and micronucleus assays; influence of XRCC1 and XRCC3 polymorphisms. Mutagenesis 20: 425–432. 10.1093/mutage/gei058.16234265
Ibrahim, R; Brix, A; Malarkey, DE; Nyska, A; Asif, M; Ramot, Y. (2021). Chemical-induced oral squamous cell neoplasms in rodents: An overview of NTP 2-year cancer studies. Toxicol Pathol. 10.1177/0192623321989956.
ICRP (International Commission on Radiological Protection). (1994). Human respiratory tract model for radiological protection. Ann ICRP 24.
ICRP (International Commission on Radiological Protection). (2006). Human alimentary tract model for radiological protection. ICRP Publication 100. A report of The International Commission on Radiological Protection. Ann ICRP 36: 25–327, iii. 10.1016/j.icrp.2006.03.004.17188183
Iijima, S; Spindle, A; Pedersen, RA. (1983). Developmental and cytogenetic effects of potassium dichromate on mouse embryos in vitro. Teratology 27: 109–115. 10.1002/tera.1420270116.6845212
Ikarashi, Y; Momma, J; Tsuchiya, T; Nakamura, A. (1996). Evaluation of skin sensitization potential of nickel, chromium, titanium and zirconium salts using guinea-pigs and mice. Biomaterials 17: 2103–2108. 10.1016/0142-9612(96)00038-5.8902244
Ikarashi, Y; Tsuchiya, T; Nakamura, A. (1992). Detection of contact sensitivity of metal salts using the murine local lymph node assay. Toxicol Lett 62: 53–61. 10.1016/0378-4274(92)90078-x.1509507
IOM (Institute of Medicine). (2011). Dietary reference intakes for calcium and vitamin D. In AC Ross; CL Taylor; AL Yaktine; HB Del Valle (Eds.). Washington, DC: National Academies Press. 10.17226/13050.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
IPCS (International Programme on Chemical Safety). (2013). Inorganic chromium(VI) compounds. (78). Geneva, Switzerland: World Health Organization. http://www.who.int/ipcs/publications/cicad/cicad_78.pdf.
Ishikawa, Y; Nakagawa, K; Satoh, Y; Kitagawa, T; Sugano, H; Hirano, T; Tsuchiya, E. (1994a). Characteristics of chromate workers' cancers, chromium lung deposition and precancerous bronchial lesions: an autopsy study. Br J Cancer 70: 160–166.8018529
Ishikawa, Y; Nakagawa, K; Satoh, Y; Kitagawa, T; Sugano, H; Hirano, T; Tsuchiya, E. (1994b). Hot spots of chromium accumulation at bifurcations of chromate workers' bronchi. Cancer Res 54: 2342–2346.8162579
Islam, LN; Rahman, F; Hossain, A. (2019). Serum Immunoglobulin Levels and Complement Function of Tannery Workers in Bangladesh. 9: 190308. 10.5696/2156-9614-9.21.190308.
Itoh, S; Shimada, H. (1997). Clastogenicity and mutagenicity of hexavalent chromium in lacZ transgenic mice. Toxicol Lett 91: 229–233.9217243
Itoh, S; Shimada, H. (1998). Bone marrow and liver mutagenesis in lacZ transgenic mice treated with hexavalent chromium. Mutat Res 412: 63–67.9508365
Izzotti, A; Bagnasco, M; Camoirano, A; Orlando, M; De Flora, S. (1998). DNA fragmentation, DNA-protein crosslinks, 32P postlabeled nucleotidic modifications, and 8-hydroxy-2'-deoxyguanosine in the lung but not in the liver of rats receiving intratracheal instillations of chromium(VI). Chemoprevention by oral N-acetylcysteine. Mutat Res Fundam Mol Mech Mutagen 400: 233–244. 10.1016/S0027-5107(98)00028-1.
Jacquet, P; Draye, JP. (1982). Toxicity of chromium salts to cultured mouse embryos. Toxicol Lett 12: 53–57. 10.1016/0378-4274(82)90198-9.7112602
Jardine, PM; Mehlhorn, TL; Bailey, WB; Brooks, SC; Fendorf, S; Gentry, RW; Phelps, TJ; Saiers, JE. (2011). Geochemical processes governing the fate and transport of chromium(III) and chromium(VI) in soils. Vadose Zone J 10: 1058–1070. 10.2136/vzj2010.0102.
Järvelä, M; Huvinen, M; Viitanen, AK; Kanerva, T; Vanhala, E; Uitti, J; Koivisto, AJ; Junttila, S; Luukkonen, R; Tuomi, T. (2016). Characterization of particle exposure in ferrochromium and stainless steel production. J Occup Environ Hyg 13: 558–568. 10.1080/15459624.2016.1159687.26950803
Jasperson, KW; Patel, SG; Ahnen, DJ. (2017). APC-Associated Polyposis Conditions. In MP Adam; HH Ardinger; RA Pagon; SE Wallace; LJH Bean; G Mirzaa; A Amemiya (Eds.), GeneReviews [Internet]. Seattle, WA: University of Washington, Seattle.
Jelnes, JE; Knudsen, LE. (1988). Stainless steel welding and semen quality. Reprod Toxicol 2: 213–215. 10.1016/0890-6238(88)90025-1.2980349
Jia, G. (2021). [Request sent to Professor Guang Jia for information from publication with reply, response to request, and follow-up attached]. Available online at (accessed
Jin, Y; Liu, L; Zhang, S; Tao, B; Tao, R; He, X; Qu, L; Huang, J; Wang, X; Fu, Z. (2016). Chromium alters lipopolysaccharide-induced inflammatory responses both in vivo and in vitro. Chemosphere 148: 436–443. 10.1016/j.chemosphere.2016.01.057.26841286
Jin, Y; Zhang, S; Tao, R; Huang, J; He, X; Qu, L; Fu, Z. (2014). Oral exposure of mice to cadmium (II), chromium (VI) and their mixture induce oxidative- and endoplasmic reticulum-stress mediated apoptosis in the livers. Environ Toxicol 31: 693–705. 10.1002/tox.22082.25409916
Jirova, D; Janeckovo, V; Znojemska, S; Pekarek, J. (1983). Adjuvant Activity Of Muramyldipeptide In A Guinea Pig Model Of Contact Allergy To Chromium. J Hyg 27: 395–402.
Johansson, A; Robertson, B; Curstedt, T; Camner, P. (1986a). Rabbit lung after inhalation of hexa-and trivalent chromium. Environ Res 41: 110–119.3757963
Johansson, A; Wiernik, A; Jarstrand, C; Camner, P. (1986b). Rabbit alveolar macrophages after inhalation of hexa- and trivalent chromium. Environ Res 39: 372–385. 10.1016/S0013-9351(86)80063-9.3956464
Johansson, MEV; Sjövall, H; Hansson, GC. (2013). The gastrointestinal mucus system in health and disease [Review]. Nat Rev Gastroenterol Hepatol 10: 352–361. 10.1038/nrgastro.2013.35.23478383
Johnson, J; Schewel, L; Graedel, TE. (2006). The contemporary anthropogenic chromium cycle. Environ Sci Technol 40: 7060–7069. 10.1021/es060061i.17154017
Jones, KB; Klein, OD. (2013). Oral epithelial stem cells in tissue maintenance and disease: the first steps in a long journey [Review]. International Journal of Oral Science 5: 121–129. 10.1038/ijos.2013.46.23887128
Jones, RP; Sutton, PA; Evans, JP; Clifford, R; Mcavoy, A; Lewis, J; Rousseau, A; Mountford, R; Mcwhirter, D; Malik, HZ. (2017). Specific mutations in KRAS codon 12 are associated with worse overall survival in patients with advanced and recurrent colorectal cancer. Br J Cancer 116: 923–929. 10.1038/bjc.2017.37.
JP, B; Olsen, JH; Hansen, KS. (1992). Adverse pregnancy outcome and childhood malignancy with reference to paternal welding exposure. Scand J Work Environ Health 18: 169–177.1615291
Juanes, MA. (2020). Cytoskeletal control and Wnt signaling-APC's dual contributions in stem cell division and colorectal cancer [Review]. Cancers 12: 3811. 10.3390/cancers12123811.33348689
Junaid, M; Murthy, RC; Saxena, DK. (1995). Chromium fetotoxicity in mice during late pregnancy. Vet Hum Toxicol 37: 320–323.8540218
Junaid, M; Murthy, RC; Saxena, DK. (1996a). Embryo and fetotoxicity of chromium in pregestationally exposed mice. Bull Environ Contam Toxicol 57: 327–334.8661917
Junaid, M; Murthy, RC; Saxena, DK. (1996b). Embryotoxicity of orally administered chromium in mice: exposure during the period of organogenesis. Toxicol Lett 84: 143–148.8600613
Kaiser, JP; Lipscomb, JC; Wesselkamper, SC. (2012). Putative mechanisms of environmental chemical-induced steatosis. Int J Toxicol 31: 551–563. 10.1177/1091581812466418.23197488
Kalahasthi, RB; Rao, RH; Murthy, RB; Kumar, MK. (2006). Effect of chromium(VI) on the status of plasma lipid peroxidation and erythrocyte antioxidant enzymes in chromium plating workers. Chem Biol Interact 164: 192–199. 10.1016/j.cbi.2006.09.012.17098216
Kalantzi, L; Goumas, K; Kalioras, V; Abrahamsson, B; Dressman, JB; Reppas, C. (2006). Characterization of the human upper gastrointestinal contents under conditions simulating bioavailability/bioequivalence studies. Pharm Res 23: 165–176. 10.1007/s11095-005-8476-1.16308672
Kaltreider, RC; Pesce, CA; Ihnat, MA; Lariviere, JP; Hamilton, JW. (1999). Differential effects of arsenic(III) and chromium(VI) on nuclear transcription factor binding. Mol Carcinog 25: 219–229. 10.1002/(SICI)1098-2744(199907)25:3<219::AID-MC8>3.0.CO;2-X.10411148
Kanojia, RK; Junaid, M; Murthy, RC. (1996). Chromium induced teratogenicity in female rat. Toxicol Lett 89: 207–213. 10.1016/S0378-4274(96)03812-X.9001589
Kanojia, RK; Junaid, M; Murthy, RC. (1998). Embryo and fetotoxicity of hexavalent chromium: a long-term study. Toxicol Lett 95: 165–172. 10.1016/S0378-4274(98)00034-4.9704818
Kararli, TT. (1995). Comparison of the gastrointestinal anatomy, physiology, and biochemistry of humans and commonly used laboratory animals [Review]. Biopharm Drug Dispos 16: 351–380. 10.1002/bdd.2510160502.8527686
Karaulov, AV; Renieri, EA; Smolyagin, AI; Mikhaylova, IV; Stadnikov, AA; Begun, DN; Tsarouhas, K; Buha Djordjevic, A; Hartung, T; Tsatsakis, A. (2019). Long-term effects of chromium on morphological and immunological parameters of Wistar rats. Food Chem Toxicol 133: 110748. 10.1016/j.fct.2019.110748.31377140
Katabami, M; Dosaka-Akita, H; Mishina, T; Honma, K; Kimura, K; Uchida, Y; Morikawa, K; Mikami, H; Fukuda, S; Inuyama, Y; Ohsaki, Y; Kawakami, Y. (2000). Frequent cyclin D1 expression in chromate-induced lung cancers. Hum Pathol 31: 973–979. 10.1053/hupa.2000.9081.10987259
Katiyar, S; Awasthi, SK; Sahu, RK. (2008). Suppression of IL-6 level in human peripheral blood mononuclear cells stimulated with PHA/LPS after occupational exposure to chromium. Sci Total Environ 390: 355–361. 10.1016/j.scitotenv.2007.10.031.18031794
Kempe, DS; Lang, PA; Duranton, C; Akel, A; Lang, KS; Huber, SM; Wieder, T; Lang, F. (2006). Enhanced programmed cell death of iron-deficient erythrocytes. FASEB J 20: 368–370. 10.1096/fj.05-4872fje.16371427
Kerger, BD; Butler, WJ; Paustenbach, DJ; Zhang, J; Li, S. (2009). Cancer mortality in chinese populations surrounding an alloy plant with chromium smelting operations. J Toxicol Environ Health A 72: 329–344. 10.1080/15287390802529898.19184749
Kerger, BD; Finley, BL; Corbett, GE; Dodge, DG; Paustenbach, DJ. (1997). Ingestion of chromium (VI) in drinking water by human volunteers: absorption, distribution, and excretion of single and repeated doses. J Toxicol Environ Health 50: 67–95.9015133
Kerger, BD; Paustenbach, DJ; Corbett, GE; Finley, BL. (1996). Absorption and elimination of trivalent and hexavalent chromium in humans following ingestion of a bolus dose in drinking water. Toxicol Appl Pharmacol 141: 145–158. 10.1006/taap.1996.0271.8917687
Khan, DA; Mushtaq, S; Khan, FA; Khan, MQA. (2013). Toxic effects of chromium on tannery workers at Sialkot (Pakistan). Toxicol Ind Health 29: 209–215. 10.1177/0748233711430974.22258629
Kiela, PR; Ghishan, FK. (2016). Physiology of intestinal absorption and secretion [Review]. Best Pract Res Clin Gastroenterol 30: 145–159. 10.1016/j.bpg.2016.02.007.27086882
Kim, H; Cho, SH; Chung, MH. (1999). Exposure to hexavalent chromium does not increase 8-hydroxydeoxyguanosine levels in Korean chromate pigment workers. Ind Health 37: 335–341.10441906
Kim, HY; Lee, SB; Jang, BS. (2004). Subchronic inhalation toxicity of soluble hexavalent chromium trioxide in rats. Arch Toxicol 78: 363–368. 10.1007/s00204-004-0553-4.15205887
Kim, JG; Dixon, JB. (2002). Oxidation and fate of chromium in soils. Soil Sci Plant Nutr 48: 483–490. 10.1080/00380768.2002.10409230.
Kim, SH; Lee, I, nC; Baek, HS; Moon, C; Kang, SS, oo; Bae, CS, ik; Kim, SH, o; Shin, DH, o; Kim, JC. (2012). Pycnogenol (R) prevents hexavalent chromium-induced spermatotoxicity in rats. Mol Cell Toxicol 8: 249–256. 10.1007/s13273-012-0030-8.
Kim, WR; Flamm, SL; Di Bisceglie, AM; Bodenheimer, HC. (2008). Serum activity of alanine aminotransferase (ALT) as an indicator of health and disease. Hepatology 47: 1363–1370. 10.1002/hep.22109.18366115
Kim, YD; An, SC; Oyama, T; Kawamoto, T; Kim, H. (2003). Oxidative stress, hogg1 expression and NF-kappaB activity in cells exposed to low level chromium. J Occup Health 45: 271–277. 10.1539/joh.45.271.14646267
Kimber, I; Bentley, AN; Hilton, J. (1990). Contact sensitization of mice to nickel sulphate and potassium dichromate. Contact Derm 23: 325–330. 10.1111/j.1600-0536.1990.tb05166.x.
Kimbrough, DE; Cohen, Y; Winer, A; Creelman, L; Mabuni, C. (1999). A critical assessment of chromium in the environment. Crit Rev Environ Sci Tech 29: 1–46. 10.1080/10643389991259164.
Kirman, CR; Aylward, LL; Suh, M; Harris, MA; Thompson, CM; Haws, LC; Proctor, DM; Lin, SS; Parker, W; Hays, SM. (2013). Physiologically based pharmacokinetic model for humans orally exposed to chromium. Chem Biol Interact 204: 13–27. 10.1016/j.cbi.2013.04.003.23603453
Kirman, CR; Hays, SM; Aylward, LL; Suh, M; Harris, MA; Thompson, CM; Haws, LC; Proctor, DM. (2012). Physiologically based pharmacokinetic model for rats and mice orally exposed to chromium. Chem Biol Interact 200: 45–64. 10.1016/j.cbi.2012.08.016.22981460
Kirman, CR; Suh, M; Hays, SM; Gürleyük, H; Gerads, R; De Flora, S; Parker, W; Lin, S; Haws, LC; Harris, MA; Proctor, DM. (2016). Reduction of hexavalent chromium by fasted and fed human gastric fluid. II. Ex vivo gastric reduction modeling. Toxicol Appl Pharmacol 306: 120–133. 10.1016/j.taap.2016.07.002.27396814
Kirman, CR; Suh, M; Proctor, DM; Hays, SM. (2017). Improved physiologically based pharmacokinetic model for oral exposures to chromium in mice, rats, and humans to address temporal variation and sensitive populations. Toxicol Appl Pharmacol 325: 9–17. 10.1016/j.taap.2017.03.023.28389273
Kirpnick-Sobol, Z; Reliene, R; Schiestl, RH. (2006). Carcinogenic Cr(VI) and the nutritional supplement Cr(III) induce DNA deletions in yeast and mice. Cancer Res 66: 3480–3484. 10.1158/0008-5472.CAN-05-3944.16585171
Kitamura, F; Yokoyama, K; Araki, S; Nishikitani, M; Choi, JW; Yum, YT; Park, HC; Park, SH; Sato, H. (2003). Increase of olfactory threshold in plating factory workers exposed to chromium in Korea. Ind Health 41: 279–285. 10.2486/indhealth.41.279.12916760
Kleinfeld, M; Rosso, A. (1965). Ulcerations of the nasal septum due to inhalation of chromic acid mist. Indian J Med Surg 34: 242–243.
Kleinstreuer, C; Zhang, Z; Donohue, JF. (2008). Targeted drug-aerosol delivery in the human respiratory system. Annu Rev Biomed Eng 10: 195–220. 10.1146/annurev.bioeng.10.061807.160544.18412536
Kodavanti, U. (2014). Respiratory toxicity biomarkers. In R Gupta (Ed.), Biomarkers in toxicology (pp. 217–239). San Diego, CA: Academic Press. 10.1016/B978-0-12-404630-6.00012-9.
Kohl, KD; Stengel, A; Samuni-Blank, M; Dearing, MD. (2013). Effects of anatomy and diet on gastrointestinal pH in rodents. J Exp Zool A Ecol Genet Physiol 319: 225–229. 10.1002/jez.1786.23460608
Kołaciński, Z; Kostrzewski, P; Kruszewska, S; Raźniewska, G; Mielczarska, J. (1999). Acute potassium dichromate poisoning: a toxicokinetic case study. J Toxicol Clin Toxicol 37: 785–791.10584593
Kolacinski, Z; Kruszewska, S; Winnicka, R; Razniewska, G; Kolacinska, M. (2004). Toxicokinetics of Chromium Elimination in Hemodialysis and Forced Diuresis Based on a Case of Potassium Dichromate Intoxication. J Toxicol Clin Toxicol 42.
Kondo, K; Hino, N; Sasa, M; Kamamura, Y; Sakiyama, S; Tsuyuguchi, M; Hashimoto, M; Uyama, T; Monden, Y. (1997). Mutations of the p53 gene in human lung cancer from chromate-exposed workers. Biochem Biophys Res Commun 239: 95–100. 10.1006/bbrc.1997.7425.9345276
Kondo, K; Takahashi, Y; Hirose, Y; Nagao, T; Tsuyuguchi, M; Hashimoto, M; Ochiai, A; Monden, Y; Tangoku, A. (2006). The reduced expression and aberrant methylation of p16(INK4a) in chromate workers with lung cancer. Lung Cancer 53: 295–302. 10.1016/j.lungcan.2006.05.022.16828922
Kondo, K; Takahashi, Y; Ishikawa, S; Uchihara, H; Hirose, Y; Yoshizawa, K; Tsuyuguchi, M; Takizawa, H; Miyoshi, T; Sakiyama, S; Monden, Y. (2003). Microscopic analysis of chromium accumulation in the bronchi and lung of chromate workers. Cancer 98: 2420–2429. 10.1002/cncr.11818.14635077
Kopec, AK; Kim, S; Forgacs, AL; Zacharewski, TR; Proctor, DM; Harris, MA; Haws, LC; Thompson, CM. (2012a). Genome-wide gene expression effects in B6C3F1 mouse intestinal epithelia following 7 and 90days of exposure to hexavalent chromium in drinking water. Toxicol Appl Pharmacol 259: 13–26. 10.1016/j.taap.2011.11.012.22155349
Kopec, AK; Thompson, CM; Kim, S; Forgacs, AL; Zacharewski, TR. (2012b). Comparative toxicogenomic analysis of oral Cr(VI) exposure effects in rat and mouse small intestinal epithelia. Toxicol Appl Pharmacol 262: 124–138. 10.1016/j.taap.2012.04.026.22561333
Korallus, U; H-J, L; Neiss, A; Zwingers, T. (1982). [Relationships between hygienic measures and the bronchial carcinoma mortality in the chromate producing industry]. Arbeitsmed Sozialmed Praventivmed 17: 159–167.
Korotzer, B; Ong, S; Hansen, JE. (2000). Ethnic differences in pulmonary function in healthy nonsmoking Asian-Americans and European-Americans. Am J Respir Crit Care Med 161: 1101–1108. 10.1164/ajrccm.161.4.9902063.10764297
Koshi, K; Yagami, T; Nakanishi, Y. (1984). Cytogenetic analysis of peripheral blood lymphocytes from stainless steel welders. Ind Health 22: 305–318. 10.2486/indhealth.22.305.6526704
Koutras, GA; Hattori, M; Schneider, AS; Ebaugh, FG; Valentine, WN. (1964). STUDIES ON CHROMATED ERYTHROCYTES. EFFECT OF SODIUM CHROMATE ON ERYTHROCYTE GLUTATHIONE REDUCTASE. J Clin Invest 43: 323–331. 10.1172/JCI104917.14162540
Koyama, Y; Brenner, DA. (2017). Liver inflammation and fibrosis [Review]. J Clin Invest 127: 55–64. 10.1172/JCI88881.28045404
Krause, DS; Theise, ND; Collector, MI; Henegariu, O; Hwang, S; Gardner, R; Neutzel, S; Sharkis, SJ. (2001). Multi-organ, multi-lineage engraftment by a single bone marrow-derived stem cell. Cell 105: 369–377. 10.1016/S0092-8674(01)00328-2.11348593
Krawic, A; Luczak, M; Zhitkovich, A. (2017). Variation in extracellular detoxification is a link to different carcinogenicity among chromates in rodent and human lungs. Chem Res Toxicol 30: 1720–1729. 10.1021/acs.chemrestox.7b00172.28759204
Krawic, C; Zhitkovich, A. (2023). Chemical mechanisms of DNA damage by carcinogenic chromium(VI). Adv Pharmacol 96: 25–46. 10.1016/bs.apha.2022.07.003.36858775
Krim, M; Messaadia, A; Maidi, I; Aouacheri, O; Saka, S. (2013). Protective effect of ginger against toxicity induced by chromate in rats. Ann Biol Clin (Paris) 71: 165–173. 10.1684/abc.2013.0806.23587580
Kumar, A; Barthwal, R. (1991). Hexavalent chromium effects on hematological indices in rats. Bull Environ Contam Toxicol 46: 761–768. 10.1007/BF01689965.1645608
Kumar, A; Rana, SVS. (1982). Lipid accumulation in chromium poisoned rats. Int J Tissue React 4: 291–295.7169300
Kumar, KM; Aruldhas, MM; Banu, SL; Sadasivam, B; Vengatesh, G; Ganesh, KM; Navaneethabalakrishnan, S; Navin, AK; Michael, FM; Venkatachalam, S; Stanley, JA; Ramachandran, I; Banu, SK; Akbarsha, MA. (2017). Male reproductive toxicity of CrVI: In-utero exposure to CrVI at the critical window of testis differentiation represses the expression of Sertoli cell tight junction proteins and hormone receptors in adult F1 progeny rats. Reprod Toxicol 69: 84–98. 10.1016/j.reprotox.2017.02.007.28192182
Kumar, S; Sathwara, NG; Gautam, AK; Agarwal, K; Shah, B; Kulkarni, PK; Patel, K; Patel, A; Dave, LM; Parikh, DJ; Saiyed, HN. (2005). Semen quality of industrial workers occupationally exposed to chromium. J Occup Health 47: 424–430.16230836
Kunstyr, I; Peters, K; Gärtner, K. (1976). Investigations on the function of the rat forestomach. Lab Anim Sci 26: 166–170.5626
Kuo, HW; Chang, SF; Wu, KY; Wu, FY. (2003). Chromium (VI) induced oxidative damage to DNA: increase of urinary 8-hydroxydeoxyguanosine concentrations (8-OHdG) among electroplating workers. Occup Environ Med 60: 590–594.12883020
Kuo, HW; Lai, JS; Lin, TI. (1997a). Concentration and size distribution of airborne hexavalent chromium in electroplating factories. Am Ind Hyg Assoc J 58: 29–32. 10.1080/15428119791013044.9018834
Kuo, HW; Lai, JS; Lin, TI. (1997b). Nasal septum lesions and lung function in workers exposed to chromic acid in electroplating factories. Int Arch Occup Environ Health 70: 272–276.9342628
Kuo, HW; Wu, ML. (2002). Effects of chromic acid exposure on immunological parameters among electroplating workers. Int Arch Occup Environ Health 75: 186–190.11954986
Kurosaki, K; Nakamura, T; Mukai, T; Endo, T. (1995). Unusual findings in a fatal case of poisoning with chromate compounds. Forensic Sci Int 75: 57–65.7590549
Lacerda, LM; Garcia, SC; da Silva, LB; de Ávila Dornelles, M; Presotto, AT; Lourenço, ED; de Franceschi, ID; Fernandes, E; Wannmacher, CMD; Brucker, N; Sauer, E; Gioda, A; Machado, AB; Oliveira, E; Trombini, TL; Feksa, LR. (2019). Evaluation of hematological, biochemical parameters and thiol enzyme activity in chrome plating workers. Environ Sci Pollut Res Int 26: 1892–1901. 10.1007/s11356-018-3755-7.30460648
Lai, JS; Kuo, HW; Liao, FC; Lien, CH. (1998). Sister chromatid exchange induced by chromium compounds in human lymphocytes. Int Arch Occup Environ Health 71: 550–553.9860164
Lanier, B; Kai, G; Marple, B; Wall, GM. (2007). Pathophysiology and progression of nasal septal perforation. Ann Allergy Asthma Immunol 99: 473–480. 10.1016/S1081-1206(10)60373-0.18219827
Laskin, DL; Malaviya, R; Laskin, JD. (2019). Role of Macrophages in Acute Lung Injury and Chronic Fibrosis Induced by Pulmonary Toxicants [Review]. Toxicol Sci 168: 287–301. 10.1093/toxsci/kfy309.30590802
Lea, T. (2015). Caco-2 cell line. In K Verhoeckx; P Cotter; I López-Expósito; C Kleiveland; T Lea; A Mackie; T Requena; D Swiatecka; H Wichers (Eds.), The impact of food bioactives on health: In vitro and ex vivo models (pp. 103–111). Cham, Switzerland: Springer. 10.1007/978-3-319-16104-4_10.
Lee, HS; Goh, CL. (1988). Occupational dermatosis among chrome platers. Contact Derm 18: 89–93. 10.1111/j.1600-0536.1988.tb02746.x.
Lee, YH; Su, SB; Huang, CC; Sheu, HM; Tsai, JC; Lin, CH; Wang, YJ; Wang, BJ. (2014). N-acetylcysteine attenuates hexavalent chromium-induced hypersensitivity through inhibition of cell death, ROS-related signaling and cytokine expression. PLoS ONE 9: e108317. 10.1371/journal.pone.0108317.25248126
Leininger, JR; Schutten, M. (2018). Chapter 4 - Oral cavity, teeth and gingiva. In AW Suttie (Ed.), Boorman's pathology of the rat (2nd ed., pp. 15–21). Cambridge, MA: Academic Press. 10.1016/B978-0-12-391448-4.00004-6.
Leoz, ML; Carballal, S; Moreira, L; Ocaña, T; Balaguer, F. (2015). The genetic basis of familial adenomatous polyposis and its implications for clinical practice and risk management [Review]. The Application of Clinical Genetics 8: 95–107. 10.2147/TACG.S51484.25931827
Levina, A; Lay, PA. (2005). Mechanistic studies of relevance to the biological activities of chromium. Coord Chem Rev 249: 281–298. 10.1016/j.ccr.2004.02.017.
Levina, A; Pham, TH; Lay, PA. (2016). Binding of chromium(III) to transferrin could be involved in detoxification of dietary chromium(III) rather than transport of an essential trace element. Angew Chem Int Ed Engl 55: 8104–8107. 10.1002/anie.201602996.27197571
Lewis, RJ, Sr; Hawley, GG. (2007). Chromium. In RJ Lewis, Sr.; GG Hawley (Eds.), Hawley's condensed chemical dictionary (15th ed., pp. 298–299). Hoboken, NJ: John Wiley & Sons. 10.1002/9780470114735.hawley03760.
Li, C; Park, S; Zhang, X; Eisenberg, LM; Zhao, H; Darzynkiewicz, Z; Xu, D. (2017). Nuclear Gene 33/Mig6 regulates the DNA damage response through an ATM serine/threonine kinase-dependent mechanism. J Biol Chem 292: 16746–16759. 10.1074/jbc.M117.803338.28842482
Li, H; Chen, Q; Li, S; Yao, W; Li, L; Shi, X; Wang, L; Castranova, V; Vallyathan, V; Ernst, E; Chen, C. (2001). Effect of Cr(VI) exposure on sperm quality: human and animal studies. Ann Occup Hyg 45: 505–511.11583652
Li, HC; Stoicov, C; Rogers, AB; Houghton, J. (2006). Stem cells and cancer: Evidence for bone marrow stem cells in epithelial cancers [Review]. World J Gastroenterol 12: 363–371. 10.3748/wjg.v12.i3.363.16489634
Li, LT; Jiang, G; Chen, Q; Zheng, JN. (2015a). Ki67 is a promising molecular target in the diagnosis of cancer [Review]. Mol Med Rep 11: 1566–1572. 10.3892/mmr.2014.2914.25384676
Li, P; Gu, Y; Yu, S; Li, Y; Yang, J; Jia, G. (2014a). Assessing the suitability of 8-OHdG and micronuclei as genotoxic biomarkers in chromate-exposed workers: a cross-sectional study. BMJ Open 4: e005979. 10.1136/bmjopen-2014-005979.
Li, P; Li, Y; Zhang, J, i; Yu, SF, a; Tong, W, ei; Hu, X; Jia, G. (2015b). Biomarkers for Lung Epithelium Injury in Occupational Hexavalent Chromium-Exposed Workers. J Occup Environ Med 57: E45–E50. 10.1097/JOM.0000000000000436.25851191
Li, Y; Hu, G; Li, P; Tang, S; Zhang, J; Jia, G. (2016). miR-3940–5p enhances homologous recombination after DSB in Cr(VI) exposed 16HBE cell. Toxicology 344–346: 1–6. 10.1016/j.tox.2016.02.003.
Li, Y; Li, P; Yu, S; Zhang, J; Wang, T; Jia, G. (2014b). miR-3940–5p associated with genetic damage in workers exposed to hexavalent chromium. Toxicol Lett 229: 319–326. 10.1016/j.toxlet.2014.06.033.24973494
Liang, Q; Xiao, Y; Liu, K; Zhong, C; Zeng, M; Xiao, F. (2018a). Cr(VI)-induced autophagy protects L-02 hepatocytes from apoptosis through the ROS-AKT-mTOR pathway. Cell Physiol Biochem 51: 1863–1878. 10.1159/000495713.30504711
Liang, Q; Zhang, Y; Huang, M; Xiao, Y; Xiao, F. (2019). Role of mitochondrial damage in Cr(VI)-induced endoplasmic reticulum stress in L-02 hepatocytes. Mol Med Rep 19: 1256–1265. 10.3892/mmr.2018.9704.30535451
Liang, Q; Zhang, Y; Zeng, M; Guan, L; Xiao, Y; Xiao, F. (2018b). The role of IP3R-SOCCs in Cr(VI)-induced cytosolic Ca2+ overload and apoptosis in L-02 hepatocytes. Toxicology Research 7: 521–528. 10.1039/c8tx00029h.30090602
Lide, D. (2008). Chromium and compounds. In CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press.
Lin, D; Triadafilopoulos, G. (2015). Dual ambulatory pH monitoring in patients with gastroesophageal reflux rendered asymptomatic with proton pump inhibitor therapy. Dig Dis Sci 60: 1343–1349. 10.1007/s10620-014-3324-y.25135815
Lin, SC; Tai, CC; Chan, CC; Wang, JD. (1994). Nasal septum lesions caused by chromium exposure among chromium electroplating workers. Am J Ind Med 26: 221–228. 10.1002/ajim.4700260207.7977397
Lindberg, E; Hedenstierna, G. (1983). Chrome plating: Symptoms, findings in the upper airways, and effects on lung function. Arch Environ Occup Health 38: 367–374.
Lindberg, M; Forslind, B; Wahlberg, JE. (1982). Reactions of epidermal keratinocytes in sensitized and non-sensitized guinea pigs after dichromate exposure: an electron microscopic study. Acta Derm Venereol 62: 389–396.6183887
Lindemann, M; Rietschel, F; Zabel, M; Grosse-Wilde, H. (2008). Detection of chromium allergy by cellular in vitro methods. Clin Exp Allergy 38: 1468–1475. 10.1111/j.1365-2222.2008.02970.x.18384428
Linos, A; Petralias, A; Christophi, CA; Christoforidou, E; Kouroutou, P; Stoltidis, M; Veloudaki, A; Tzala, E; Makris, KC; Karagas, MR. (2011). Oral ingestion of hexavalent chromium through drinking water and cancer mortality in an industrial area of Greece--an ecological study. Environ Health 10: 50. 10.1186/1476-069X-10-50.21609468
Linqing, Y; Bo, X; Xueqin, Y; Hong, D; Desheng, W; Huimin, Z; Gaofeng, J; Jianjun, L; Zhixiong, Z. (2016). Mitochondrial DNA hypomethylation in chrome plating workers. Toxicol Lett 243: 1–6. 10.1016/j.toxlet.2015.11.031.26656300
Lischka, G. (1971). [Lymphocyte transformation test in chromium-hypersensitivity]. 240: 212–218.
Littorin, M; Hogstedt, B; Stromback, B; Karlsson, A; Welinder, H; Mitelman, F; Skerfving, S. (1983). No cytogenetic effects in lymphocytes of stainless steel welders. Scand J Work Environ Health 9: 259–264.6612267
Liu, S; Medvedovic, M; Dixon, K. (1999). Mutational specificity in a shuttle vector replicating in chromium(VI)-treated mammalian cells. Environ Mol Mutagen 33: 313–319. 10.1002/(SICI)1098-2280(1999)33:4<313::AID-EM8>3.0.CO;2-V.10398379
Locke, WJ; Guanzon, D; Ma, C; Liew, YJ; Duesing, KR; Fung, K; Ross, JP. (2019). DNA methylation cancer biomarkers: Translation to the clinic [Review]. Front Genet 10: 1150. 10.3389/fgene.2019.01150.31803237
Long, C; Liu, J; Hu, G; Feng, H; Zhou, D; Wang, J; Zhai, X; Zhao, Z; Yu, S; Wang, T; Jia, G. (2019). Modulation of homologous recombination repair gene polymorphisms on genetic damage in chromate exposed workers. Environ Toxicol Pharmacol 66: 126–132. 10.1016/j.etap.2019.01.004.30677706
Losi, ME; Amrhein, C; Frankenberger, WT. (1994). Environmental biochemistry of chromium [Review]. Rev Environ Contam Toxicol 136: 91–121. 10.1007/978-1-4612-2656-7_3.8029492
Loubières, Y; de Lassence, A; Bernier, M; Vieillard-Baron, A; Schmitt, JM; Page, B; Jardin, F. (1999). Acute, fatal, oral chromic acid poisoning. J Toxicol Clin Toxicol 37: 333–336.10384798
Lu, J; Tang, M; Liu, Y; Wang, J; Wu, Z. (2018). Comparative Proteomics of Chromium-Transformed Beas-2B Cells by 2D-DIGE and MALDI-TOF/TOF MS. Biol Trace Elem Res. 10.1007/s12011-017-1222-9.
Lucas, JB. (1976). Health Hazard Evaluation Determination, Report No. HHE-74–111-283, Cook Paint and Varnish Company, North Kansas City, Missouri, April 1976 (pp. 74–111). (NIOSH/00099446). Lucas, JB.
Lucas, JB; Kramkowski, RS. (1975). Health Hazard Evaluation Report No. HHE-74–87-221, Industrial Platers, Inc., Columbus, Ohio (pp. 74–87). (NIOSH/00049983). Cincinnati, OH: National Inst. for Occupational Safety and Health.
Luczak, MW; Green, SE; Zhitkovich, A. (2016). Different ATM Signaling in Response to Chromium(VI) Metabolism via Ascorbate and Nonascorbate Reduction: Implications for in Vitro Models and Toxicogenomics. Environ Health Perspect 124: 61–66. 10.1289/ehp.1409434.25977998
Luczak, MW; Krawic, C; Zhitkovich, A. (2019). p53 Activation by Cr(VI): A transcriptionally limited response induced by ATR kinase in s-phase. Toxicol Sci 172: 11–22. 10.1093/toxsci/kfz178.31388677
Luippold, RS; Mundt, KA; Dell, LD; Birk, T. (2005). Low-level hexavalent chromium exposure and rate of mortality among US chromate production employees. J Occup Environ Med 47: 381–385. 10.1097/01.jom.0000158703.32263.0d.15824629
Lum, G. (1995). Significance of low serum alkaline phosphatase activity in a predominantly adult male population. Clin Chem 41: 515–518.7720239
Luo, D; Xu, Z; Hu, X; Zhang, F; Bian, H; Li, N; Wang, Q; Lu, Y; Zheng, Q; Gu, J. (2016). URI prevents potassium dichromate-induced oxidative stress and cell death in gastric cancer cells. 8: 5399–5409.
Luo, H; Lu, Y; Shi, X; Mao, Y; Dalal, NS. (1996). Chromium (IV)-mediated fenton-like reaction causes DNA damage: implication to genotoxicity of chromate. Ann Clin Lab Sci 26: 185–191.8852428
Lupescu, A; Jilani, K; Zelenak, C; Zbidah, M; Qadri, SM; Lang, F. (2012). Hexavalent chromium-induced erythrocyte membrane phospholipid asymmetry. Biometals 25: 309–318. 10.1007/s10534-011-9507-5.22080200
Luster, MI; Portier, C; Pait, DG; Rosenthal, GJ; Germolec, DR; Corsini, E; Blaylock, BL; Pollock, P; Kouchi, Y; Craig, W. (1993). Risk assessment in immunotoxicology. II. Relationships between immune and host resistance tests. Fundam Appl Toxicol 21: 71–82.8365588
Luster, MI; Portier, C; Pait, DG; White, KL, Jr; Gennings, C; Munson, AE; Rosenthal, GJ. (1992). Risk assessment in immunotoxicology. I. Sensitivity and predictability of immune tests. Fundam Appl Toxicol 18: 200–210. 10.1016/0272-0590(92)90047-L.1534777
Lv, Y; Zhang, P; Guo, J; Zhu, Z; Li, X; Xu, D; Zeng, W. (2018). Melatonin protects mouse spermatogonial stem cells against hexavalent chromium-induced apoptosis and epigenetic histone modification. Toxicol Appl Pharmacol 340: 30–38. 10.1016/j.taap.2017.12.017.29289671
Lytle, CM; Lytle, FW; Yang, N; Qian, JH; Hansen, D; Zayed, A; Terry, N. (1998). Reduction of Cr(VI) to Cr(III) by wetland plants: Potential for in situ heavy metal detoxification. Environ Sci Technol 32: 3087–3093.
Macfie, A; Hagan, E; Zhitkovich, A. (2010). Mechanism of DNA-protein cross-linking by chromium. Chem Res Toxicol 23: 341–347. 10.1021/tx9003402.19877617
Macgregor, JT; Wehr, CM; Henika, PR; Shelby, MD. (1990). The in vivo erythrocyte micronucleus test: Measurement at steady state increases assay efficiency and permits integration with toxicity studies. Fundam Appl Toxicol 14: 513–522. 10.1016/0272-0590(90)90255-I.2111256
Machle, W; Gregorius, F. (1948). Cancer of the respiratory system in the United States chromate-producing industry. Public Health Rep 63: 1114–1127. 10.2307/4586677.18878263
MacKenzie, RD; Byerrum, RU; Decker, CF; Hoppert, CA; Langham, RF. (1958). Chronic toxicity studies. II. Hexavalent and trivalent chromium administered in drinking water to rats. AMA Arch Ind Health 18: 232–234.13570713
Maeng, SH; Chung, HW; Kim, KJ; Lee, BM; Shin YC Kim, SJ; Yu, IJ. (2004). Chromosome aberration and lipid peroxidation in chromium-exposed workers. Biomarkers 9: 418–434. 10.1080/13547500400022200.15849063
Maeng, SH; Chung, HW; Yu, IJ; Kim, HY; Lim, CH; Kim, KJ; Kim, SJ; Ootsuyama, Y; Kasai, H. (2003). Changes of 8-OH-dG levels in DNA and its base excision repair activity in rat lungs after inhalation exposure to hexavalent chromium. Mutat Res 539: 109–116. 10.1016/S1383-5718(03)00154-2.12948819
Malsch, PA; Proctor, DM; Finley, BL. (1994). Estimation of a chromium inhalation reference concentration using the benchmark dose method: A case study [Review]. Regul Toxicol Pharmacol 20: 58–82. 10.1006/rtph.1994.1036.7838992
Mancuso, TF. (1951). Occupational cancer and other health hazards in a chromate plant: A medical appraisal. II. Clinical and toxicologic aspects. Ind Med Surg 20: 393–407.14860912
Mancuso, TF. (1975). Consideration of chromium as an industrial carcinogen. In International conference on heavy metals in the environment: v III, health; October. Toronto, ON, Canada: Institute for Environmental Studies.
Mancuso, TF. (1997). Chromium as an industrial carcinogen: Part I. Am J Ind Med 31: 129–139. 10.1002/(SICI)1097-0274(199702)31:2<129::AID-AJIM1>3.0.CO;2-V.9028428
Mandervelt, C; Clottens, FL; Demedts, M; Nemery, B. (1997). Assessment of the sensitization potential of five metal salts in the murine local lymph node assay. Toxicology 120: 65–73.9160110
Marat, I; Arstan, M; Galymzhan, Y; Timur, J; Yerbolat, I; Almasbek, Y. (2018). Impact of chromium and boron compounds on the reproductive function in rats. Toxicol Ind Health 34: 365–374. 10.1177/0748233718759162.29591889
Margonis, GA; Kim, Y; Spolverato, G; Ejaz, A; Gupta, R; Cosgrove, D; Anders, R; Karagkounis, G; Choti, MA; Pawlik, TM. (2015). Association between specific mutations in KRAS codon 12 and colorectal liver metastasis. JAMA Surgery 150: 722–729. 10.1001/jamasurg.2015.0313.26038887
Marin, RA; Bose, R; Dabrowski, B; Kolesnik, S. (2018). Magnetic Characterization of Chromium Intermediates in the Reduction of Chromium (VI) by Glutathione in Acidic Solutions. 4. 10.3390/magnetochemistry4020023.
Markovich, D; James, KM. (1999). Heavy metals mercury, cadmium, and chromium inhibit the activity of the mammalian liver and kidney sulfate transporter sat-1. Toxicol Appl Pharmacol 154: 181–187. 10.1006/taap.1998.8559.9925802
Markovich, D; Knight, D. (1998). Renal Na-Si cotransporter NaSi-1 is inhibited by heavy metals. Am J Physiol 274: F283–F289.9486223
Marouani, N; Tebourbi, O; Hallègue, D; Mokni, M; Yacoubi, MT; Sakly, M; Benkhalifa, M; Rhouma, KB. (2015a). Mechanisms of chromium hexavalent-induced apoptosis in rat testes. Toxicol Ind Health 33: 97–106. 10.1177/0748233715600333.
Marouani, N; Tebourbi, O; Mahjoub, S; Yacoubi, MT; Sakly, M; Benkhalifa, M; Rhouma, KB. (2012). Effects of hexavalent chromium on reproductive functions of male adult rats. Reprod Biol 12: 119–133.22850466
Marouani, N; Tebourbi, O; Mokni, M; Yacoubi, MT; Sakly, M; Benkhalifa, M; Ben Rhouma, K. (2015b). Hexavalent chromium-induced apoptosis in rat uterus: Involvement of oxidative stress. Arch Environ Occup Health 70: 189–195. 10.1080/19338244.2013.828673.24965329
Martin, BD; Schoenhard, JA; Hwang, JM; Sugden, KD. (2006). Ascorbate is a pro-oxidant in chromium-treated human lung cells. Mutat Res 610: 74–84. 10.1016/j.mrgentox.2006.06.014.16857421
Martino, J; Holmes, AL; Xie, H; Wise, SS; Wise, JP. (2015). Chronic Exposure to Particulate Chromate Induces Premature Centrosome Separation and Centriole Disengagement in Human Lung Cells. Toxicol Sci 147: 490–499. 10.1093/toxsci/kfv146.26293554
Marynka-Kalmani, K; Treves, S; Yafee, M; Rachima, H; Gafni, Y; Cohen, MA; Pitaru, S. (2010). The lamina propria of adult human oral mucosa harbors a novel stem cell population. Stem Cells 28: 984–995. 10.1002/stem.425.20474080
Mathebula, MW; Mandiwana, K; Panichev, N. (2017). Speciation of chromium in bread and breakfast cereals. Food Chem 217: 655–659. 10.1016/j.foodchem.2016.09.020.27664683
McClain, CN; Fendorf, S; Webb, SM; Maher, K. (2017). Quantifying Cr(VI) production and export from serpentine soil of the California coast range. Environ Sci Technol 51: 141–149. 10.1021/acs.est.6b03484.27935688
Mcconnell, EL; Basit, AW; Murdan, S. (2008). Measurements of rat and mouse gastrointestinal pH, fluid and lymphoid tissue, and implications for in-vivo experiments. J Pharm Pharmacol 60: 63–70. 10.1211/jpp.60.1.0008.18088506
Mckinzie, PB; Parsons, BL. (2002). Detection of rare K-ras codon 12 mutations using allele-specific competitive blocker PCR. Mutat Res 517: 209–220. 10.1016/s1383-5718(02)00077-3.12034322
Mckinzie, PB; Parsons, BL. (2011). Accumulation of K-Ras codon 12 mutations in the F344 rat distal colon following azoxymethane exposure. Environ Mol Mutagen 52: 409–418. 10.1002/em.20644.21370285
Medeiros, MG; Rodrigues, AS; Batoréu, MC; Laires, A; Rueff, J; Zhitkovich, A. (2003). Elevated levels of DNA-protein crosslinks and micronuclei in peripheral lymphocytes of tannery workers exposed to trivalent chromium. Mutagenesis 18: 19–24.12473731
Meenakshi, CE; Padmini, E; Motlag, DB. (1989). Comparative toxicity of trivalent and hexavalent chromium in rats. Indian J Environ Health 31: 250–256.
Melcher, R; Koehler, S; Steinlein, C; Schmid, M; Mueller, CR; Luehrs, H; Menzel, T; Scheppach, W; Moerk, H; Scheurlen, M; Koehrle, J; Al-Taie, O. (2002). Spectral karyotype analysis of colon cancer cell lines of the tumor suppressor and mutator pathway. Cytogenet Genome Res 98: 22–28. 10.1159/000068544.12584437
Meng, F; Knapp, GW; Green, T; Ross, JA; Parsons, BL. (2010). K-Ras mutant fraction in A/J mouse lung increases as a function of benzo[a]pyrene dose. Environ Mol Mutagen 51: 146–155. 10.1002/em.20513.19658153
Mezencev, R; Auerbach, SS. (2021). Inferred inactivation of the Cftr gene in the duodena of mice exposed to hexavalent chromium (Cr(VI)) in drinking water supports its tumor-suppressor status and implies its potential role in Cr(VI)-induced carcinogenesis of the small intestines. Toxicol Appl Pharmacol 433: 115773. 10.1016/j.taap.2021.115773.
Mezencev, R; Gibbons, C. (2023). Interactions between chromium species and DNA in vitro and their potential role in the toxicity of hexavalent chromium. Metallomics 15. 10.1093/mtomcs/mfad045.
Miettinen, M; Torvela, T; Leskinen, JT. (2016). Physicochemical characterization of aerosol generated in the gas tungsten arc welding of stainless steel. Ann Occup Hyg 60: 960–968. 10.1093/annhyg/mew039.27390355
Migliore, L; Parrini, M; Sbrana, I; Biagini, C; A; Loprieno, N. (1991). Micronucleated lymphocytes in people occupationally exposed to potential environmental contaminants: The age effect. Mutat Res 256: 13–20. doi:10.1016/0921-8734(91)90028-A.1944383
Mignini, F; Streccioni, V; Baldo, M; Vitali, M; Indraccolo, U; Bernacchia, G; Cocchioni, M. (2004). Individual susceptibility to hexavalent chromium of workers of shoe, hide, and leather industries. Immunological pattern of HLA-B8, DR3-positive subjects. Prev Med 39: 767–775. 10.1016/j.ypmed.2004.02.048.15351544
Mignini, F; Tomassoni, D; Traini, E; Vitali, M; Scuri, S; Baldoni, E; Grappasonni, I; Cocchioni, M. (2009). Immunological pattern alteration in shoe, hide, and leather industry workers exposed to hexavalent chromium. Environ Toxicol 24: 594–602. 10.1002/tox.20464.19051261
Mignot, L; Junte, GA. (1990). Diffusion in immobilized-cell agar layers: Influence of bacterial growth on the diffusivity of potassium chloride. Appl Microbiol Biotechnol 33: 167–171. 10.1007/BF00176519.1366531
Miksche, LW; Lewalter, J. (1997). Health surveillance and biological effect monitoring for chromium-exposed workers [Review]. Regul Toxicol Pharmacol 26: S94–S99. 10.1006/rtph.1997.1146.9380843
Miller, AC; Comellas, AP; Hornick, DB; Stoltz, DA; Cavanaugh, JE; Gerke, AK; Welsh, MJ; Zabner, J; Polgreen, PM. (2020). Cystic fibrosis carriers are at increased risk for a wide range of cystic fibrosis-related conditions. Proc Natl Acad Sci USA 117: 1621–1627. 10.1073/pnas.1914912117.31882447
Mills, JC; Shivdasani, RA. (2011). Gastric epithelial stem cells [Review]. Gastroenterology 140: 412–424. 10.1053/j.gastro.2010.12.001.21144849
Mirsalis, JC; Hamilton, CM; OĽoughlin, KG; Paustenbach, DJ; Kerger, BD; Patierno, S. (1996). Chromium (VI) at plausible drinking water concentrations is not genotoxic in the in vivo bone marrow micronucleus or liver unscheduled DNA synthesis assays. Environ Mol Mutagen 28: 60–63. 10.1002/(SICI)1098-2280(1996)28:1<60::AID-EM9>3.0.CO;2-I.8698048
Mitrov, D; Hadzi-Petrushev, N; Stojkovski, V; Gjorgievska, E; Gagov, H; Mladenov, M. (2014). Influence of chronic chromium exposition on the processes of lipid peroxidation inflammation and platelet activation in rats [Letter]. J Biol Regul Homeost Agents 28: 531–535.25316141
Miyamoto, T; Ichikawa, K; Kabe, J; Horiuchi, Y. (1975). Delayed-type hypersensitivity reaction in the lungs of guinea pigs due to potassium dichromate. J Allergy Clin Immunol 56: 464–472.1206185
Mo, J; Tang, C; Wang, X; Lu, W; Tong, H, ui; Zhang, C; Zhang, G. (2018). Histopathological analysis of ductular reaction in rabbit liver after chronic exposure of chromium (VI). Acta med Mediterr 34: 1213–1219. 10.19193/0393-6384_2018_5_186.
Monserrat-Mesquida, M; Quetglas-Llabrés, M; Abbate, M; Montemayor, S; Mascaró, CM; Casares, M; Tejada, S; Abete, I; Zulet, MA; Tur, JA; Martínez, JA; Sureda, A. (2020). Oxidative stress and pro-inflammatory status in patients with non-alcoholic fatty liver disease. Antioxidants 9: 759. 10.3390/antiox9080759.32824349
Mor, S; Ben-Efraim, S; Leibovici, J; Ben-David, A. (1988). Successful contact sensitization to chromate in mice. International Arch Allergy Appl Immunol 85: 452–457. 10.1159/000234550.
Morihara, M; Aoyagi, N; Kaniwa, N; Kojima, S; Ogata, H. (2001). Assessment of gastric acidity of Japanese subjects over the last 15 years. Biol Pharm Bull 24: 313–315. 10.1248/bpb.24.313.11256493
Moschandreas, DJ; Karuchit, S; Berry, MR; O'Rourke, MK; Lo, D; Lebowitz, MD; Robertson, G. (2002). Exposure apportionment: ranking food items by their contribution to dietary exposure. J Expo Anal Environ Epidemiol 12: 233–243. 10.1038/sj.jea.7500230.12087429
Moulin, JJ; Clavel, T; Roy, D; Dananché, B; Marquis, N; Févotte, J; Fontana, JM. (2000). Risk of lung cancer in workers producing stainless steel and metallic alloys. Int Arch Occup Environ Health 73: 171–180. 10.1007/s004200050024.10787132
Moulin, JJ; Portefaix, P; Wild, P; Mur, JM; Smagghe, G; Mantout, B. (1990). Mortality study among workers producing ferroalloys and stainless steel in France. Br J Ind Med 47: 537–543. 10.1136/oem.47.8.537.2393634
Moulin, JJ; Wild, P; Haguenoer, JM; Faucon, D; De Gaudemaris, R; Mur, JM; Mereau, M; Gary, Y; Toamain, JP; Birembaut, Y. (1993a). A mortality study among mild steel and stainless steel welders. Br J Ind Med 50: 234–243. 10.1136/oem.50.3.234.8457490
Moulin, JJ; Wild, P; Mantout, B; Fournier-Betz, M; Mur, JM; Smagghe, G. (1993b). Mortality from lung cancer and cardiovascular diseases among stainless-steel producing workers. Cancer Causes Control 4: 75–81. 10.1007/BF00053147.8386949
Mozafari, P; Rezazadeh Azari, M; Shokoohi, Y; Sayadi, M. (2016). Feasibility of biological effective monitoring of chrome electroplaters to chromium through analysis of serum malondialdehyde. Int J Occup Environ Med 7: 199–206. 10.15171/ijoem.2016.782.27651080
Mudie, DM; Amidon, GL; Amidon, GE. (2010). Physiological parameters for oral delivery and in vitro testing [Review]. Mol Pharm 7: 1388–1405. 10.1021/mp100149j.20822152
Mukherjee, P; Poddar, S; Talukder, G; Sharma, A. (1999). Protection by black tea extract against chromosome damage induced by two heavy metals in mice. Pharmaceutical Biology 37: 243–247. 10.1076/phbi.37.3.243.6309.
Mukherjee, P; Sarkar, D; Sharma, A. (1997). Effects of dietary consumption of black tea infusion alone and in combination with known clastogens on mouse bone marrow chromosomes in vivo. Food Chem Toxicol 35: 657–661. 10.1016/s0278-6915(97)00044-6.9301648
Muller, CD; Garcia, SC; Brucker, N; Goethel, G; Sauer, E; Lacerda, LM; Oliveira, E; Trombini, TL; Machado, AB; Pressotto, A; Rech, VC; Klauck, CR; da Silva, LB; Gioda, A; Feksa, LR. (2020). Occupational risk assessment of exposure to metals in chrome plating workers. Drug Chem Toxicol 45: 1–8. 10.1080/01480545.2020.1731527.32013615
Murphy, K; Weaver, C. (2016). Janeway's immunobiology (9th ed.). New York, NY: Garland Science.
Murthy, RC; Junaid, M; Saxena, DK. (1996). Ovarian dysfunction in mice following chromium (VI) exposure. Toxicol Lett 89: 147–154. 10.1016/S0378-4274(96)03803-9.8960157
Murthy, RC; Saxena, DK; Gupta, SK; Chandra, SV. (1991). Ultrastructural observations in testicular tissue of chromium-treated rats. Reprod Toxicol 5: 443–447. 10.1016/0890-6238(91)90008-4.1806154
Myers, CR; Antholine, WE; Myers, JM. (2010). The pro-oxidant chromium(VI) inhibits mitochondrial complex I, complex II, and aconitase in the bronchial epithelium: EPR markers for Fe-S proteins. Free Radic Biol Med 49: 1903–1915. 10.1016/j.freeradbiomed.2010.09.020.20883776
Myers, JM; Antholine, WE; Myers, CR. (2008). Hexavalent Chromium Causes the Oxidation of Thioredoxin in Human Bronchial Epithelial Cells. Toxicology 246(2–3): 222–233. 10.1016/j.tox.2008.01.017.18328613
Myers, JM; Antholine, WE; Myers, CR. (2011). The intracellular redox stress caused by hexavalent chromium is selective for proteins that have key roles in cell survival and thiol redox control. Toxicology 281: 37–47. 10.1016/j.tox.2011.01.001.21237240
Myers, JM; Myers, CR. (2009). The effects of hexavalent chromium on thioredoxin reductase and peroxiredoxins in human bronchial epithelial cells. Free Radic Biol Med 47: 1477–1485. 10.1016/j.freeradbiomed.2009.08.015.19703554
Nagaya, T. (1986). No increase in sister-chromatid exchange frequency in lymphocytes of chromium platers. Mutat Res 170: 129–132.3713723
Nagaya, T; Ishikawa, N; Hata, H. (1989). Sister chromatid exchange analysis in lymphocytes of workers exposed to hexavalent chromium. Br J Ind Med 46: 48–51.2920143
Nagaya, T; Ishikawa, N; Hata, H; Otobe, T. (1991). Sister-chromatid exchanges in lymphocytes from 12 chromium platers: a 5-year follow-up study. Toxicol Lett 58: 329–335.1957328
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA's ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Nature. (2019). Cytokines in the balance [Editorial]. Nat Immunol 20: 1557. 10.1038/s41590-019-0557-0.31745347
Navin, AK; Aruldhas, MM; Navaneethabalakrishnan, S; Mani, K; Michael, FM; Srinivasan, N; Banu, SK. (2021). Prenatal exposure to hexavalent chromium disrupts testicular steroidogenic pathway in peripubertal F1 rats. Reprod Toxicol 101: 63–73. 10.1016/j.reprotox.2021.01.014.33675932
Navya, K; Kumar, GP; Anilakumar, KR. (2017a). Ameliorating effect of Curculigo orchoides on chromium(VI) induced oxidative stress via, modulation of cytokines, transcription factors and apoptotic genes. J Appl Biomed 15: 299–306. 10.1016/j.jab.2017.03.003.
Navya, K; Phani Kumar, G; Chandrasekhar, Y; Anilakumar, KR. (2017b). Evaluation of potassium dichromate (K2Cr2O7)-induced liver oxidative stress and ameliorative effect of Picrorhiza kurroa extract in Wistar albino rats. Biol Trace Elem Res 184: 154–164. 10.1007/s12011-017-1172-2.28990134
Neal-Kluever, A; Fisher, J; Grylack, L; Kakiuchi-Kiyota, S; Halpern, W. (2019). Physiology of the Neonatal Gastrointestinal System Relevant to the Disposition of Orally Administered Medications. Drug Metab Dispos 47: 296–313. 10.1124/dmd.118.084418.30567878
Negrini, S; Gorgoulis, VG; Halazonetis, TD. (2010). Genomic instability — an evolving hallmark of cancer [Review]. Nat Rev Mol Cell Biol 11: 220–228. 10.1038/nrm2858.20177397
Nettesheim, P; Hanna, MG, Jr; Doherty, DG; Newell, RF; Hellman, A. (1971). Effect of calcium chromate dust, influenza virus, and 100 R whole-body X radiation on lung tumor incidence in mice. J Natl Cancer Inst 47: 1129–1144.10787327
Nettesheim, P; Hanna, MG, Jr; Doherty, DG; Newell, RF; Hellman, A. (1970). Effect of chronic exposure to air pollutants on the respiratory tracts of mice: Histopathological findings. In P Nettesheim; MG Hanna, Jr.; JW Deatherage, Jr. (Eds.), Morphology of experimental respiratory carcinogenesis: proceedings of a biology division, Oak Ridge National Laboratory conference; May; Gatlinburg, TN. Oak Ridge, TN: U.S. Atomic Energy Commission.
Newman, MC. (2008). "What exactly are you inferring?" A closer look at hypothesis testing. Environ Toxicol Chem 27: 1013–1019. 10.1897/07-373.1.18419185
Ng, AW; Bidani, A; Heming, TA. (2004). Innate host defense of the lung: effects of lung-lining fluid pH [Review]. Lung 182: 297–317. 10.1007/s00408-004-2511-6.15742242
Nguyen, HT; Duong, HQ. (2018). The molecular characteristics of colorectal cancer: Implications for diagnosis and therapy [Review]. Oncol Lett 16: 9–18. 10.3892/ol.2018.8679.29928381
Nickens, KP; Patierno, SR; Ceryak, S. (2010). Chromium genotoxicity: A double-edged sword [Review]. Chem Biol Interact xx: xxx. 10.1016/j.cbi.2010.04.018.
Nielsen, J; Dahlqvist, M; Welinder, H; Thomassen, Y; Alexandersson, R; Skerfving, S. (1993). Small airways function in aluminium and stainless steel welders. Int Arch Occup Environ Health 65: 101–105. 10.1007/BF00405727.8253506
NIH (National Institutes of Health). (2017). Dietary supplement fact sheet: Chromium — health professional fact sheet. Available online at https://ods.od.nih.gov/factsheets/ChromiumHealthProfessional/ (accessed June 12, 2017).
Nijs, M; Kirsch-Volders, M. (1986). Induction of spindle inhibition and abnormal mitotic figures by Cr(II), Cr(III) and Cr(VI) ions. Mutagenesis 1: 247–252. 10.1093/mutage/1.4.247.2457779
Nikula, KJ; Mccartney, JE; Mcgovern, T; Miller, GK; Odin, M; Pino, MV; Reed, MD. (2014). STP Position Paper: Interpreting the Significance of Increased Alveolar Macrophages in Rodents Following Inhalation of Pharmaceutical Materials. Toxicol Pathol 42: 472–486. 10.1177/0192623313507003.24178583
Ning, J; Grant, MH. (1999). Chromium (VI)-induced cytotoxicity to osteoblast-derived cells. Toxicol In Vitro 13: 879–887.20654563
Ning, J; Grant, MH. (2000). The role of reduced glutathione and glutathione reductase in the cytotoxicity of chromium (VI) in osteoblasts. Toxicol In Vitro 14: 329–335.10906439
Ning, J; Henderson, C; Grant, MH. (2002). The cytotoxicity of chromium in osteoblasts: Effects on macromolecular synthesis. J Mater Sci Mater Med 13: 47–52. 10.1023/A:1013630401959.15348204
NIOSH (National Institute for Occupational Safety and Health). (1972). Chromic acid mist in air. In Physical and Chemical Analysis Branch. (NIOSH/00051221). Rockville, MD.
NIOSH (National Institute for Occupational Safety and Health). (2013). Criteria for a recommended standard: Occupational exposure to hexavalent chromium. (NIOSH Publication Number 2013–128). Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/docs/2013-128/pdfs/2013_128.pdf?id=10.26616/NIOSHPUB2013128.
NIOSH (National Institute for Occupational Safety and Health). (2020). Chromium, hexavalent: Method 7600, Issue 3, dated 20 October 2015. In R Andrews; PF O’Connor (Eds.), NIOSH manual of analytical methods (NMAM) (5th ed.). Washington, DC. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7600.pdf.
Nohmi, T; Katoh, M; Suzuki, H; Matsui, M; Yamada, M; Watanabe, M; Suzuki, M; Horiya, N; Ueda, O; Shibuya, T; Ikeda, H; Sofuni, T. (1996). A new transgenic mouse mutagenesis test system using Spi- and 6-thioguanine selections. Environ Mol Mutagen 28: 465–470. 10.1002/(SICI)1098-2280(1996)28:4<465::AID-EM24>3.0.CO;2-C.8991079
Nolte, T; Brander-Weber, P; Dangler, C; Deschl, U; Elwell, MR; Greaves, P; Hailey, R; Leach, MW; Pandiri, AR; Rogers, A; Shackelford, CC; Spencer, A; Tanaka, T; Ward, JM. (2016). Nonproliferative and proliferative lesions of the gastrointestinal tract, pancreas and salivary glands of the rat and mouse [Review]. J Toxicol Pathol 29(1 Suppl.): 1S-125S. 10.1293/tox.29.1S.
Norppa, H; Bonassi, S; Hansteen, IL; Hagmar, L; Strömberg, U; Rössner, P; Boffetta, P; Lindholm, C; Gundy, S; Lazutka, J; Cebulska-Wasilewska, A; Fabiánová, E; Srám, RJ; Knudsen, LE; Barale, R; Fucic, A. (2006). Chromosomal aberrations and SCEs as biomarkers of cancer risk [Review]. Mutat Res 600: 37–45. 10.1016/j.mrfmmm.2006.05.030.16814813
NRC (National Research Council). (1988). Health risks of radon and other internally deposited alpha emitters: BEIR IV. Washington, DC. http://books.nap.edu/openbook.php?record_id=1026&page=R1.
NRC (National Research Council). (2001). Standing operating procedures for developing acute exposure guideline levels (AEGLs) for hazardous chemicals. Washington, DC: National Academies Press. 10.17226/10122.
NRC (National Research Council). (2011). Review of the Environmental Protection Agency's draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142.
Nriagu, JO. (1989). A global assessment of natural sources of atmospheric trace metals. Nature 338: 47–49. 10.1038/338047a0.
Nriagu, JO; Pacyna, JM. (1988). Quantitative assessment of worldwide contamination of air, water and soils by trace metals. Nature 333: 134–139. 10.1038/333134a0.3285219
NTP (National Toxicology Program). (1996a). Final report on the reproductive toxicity of potassium dichromate (hexavalent) (CAS No. 7778–50-9) administered in diet to BALB/c mice [NTP]. Research Triangle Park: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB97125363.xhtml.
NTP (National Toxicology Program). (1996b). Final report on the reproductive toxicity of potassium dichromate (hexavalent) (CAS No. 7778–50-9) administered in diet to SD rats [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB97125355.xhtml.
NTP (National Toxicology Program). (1997). Final report on the reproductive toxicity of potassium dichromate (CAS No. 7778–50-9) administered in diet to BALB/c mice [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB97144919.xhtml.
NTP. (2005). Immunotoxicity of hexavalent chromium in female B6C3F1 mice. Protocol: RF-HCR-28–1 M-DW. RTP: NIEHS.
NTP. (2006a). Immunotoxicity of hexavalent chromium in female Fischer 344 rats. Protocol: RF-HCR-28–2R-DW. RTP: NIEHS.
NTP. (2006b). Immunotoxicity of hexavalent chromium in female Sprague Dawley rats. Protocol: RF-HCR-28–1R-DW. RTP: NIEHS.
NTP (National Toxicology Program). (2007). NTP technical report on the toxicity studies of sodium dichromate dihydrate (CAS No. 7789–12-0) administered in drinking water to male and female F344/N rats and B6C3F1 mice and male BALB/c and am3-C57BL/6 mice. (Toxicity Report Series Number 72; NIH Publication No. 07–5964). Research Triangle Park, NC. https://ntp.niehs.nih.gov/publications/reports/tox/000s/tox072.
NTP (National Toxicology Program). (2008). Toxicology and carcinogenesis studies of sodium dichromate dihydrate (Cas No. 7789–12-0) in F344/N rats and B6C3F1 mice (drinking water studies) (pp. 1–192). (NTP TR 546; NIH Publication No. 08–5887).
NTP (National Toxicology Program). (2010). NTP technical report on the toxicology and carcinogenesis studies of chromium picolinate monohydrate (CAS No. 27882–76-4) in F344/N rats and B6C3F1 mice (feed studies). (NTP TR 556; NIH Publication No. 10–5897). Research Triangle Park, NC. https://ntp.niehs.nih.gov/publications/reports/tr/500s/tr556.
NTP (National Toxicology Program). (2011). Report on carcinogens. Twelfth Edition, 2011 (12th ed., pp. 507). (NTP TR 581 126). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2011111646.xhtml.
NTP (National Toxicology Program). (2020). Organ sites with neoplasia: number of test articles associated with site-specific neoplasia that produced positive, clear or some evidence of carcinogenicity. Available online at https://manticore.niehs.nih.gov/organsites/ (accessed
Nudler, SI; Quinteros, FA; Miler, EA; Cabilla, JP; Ronchetti, SA; Duvilanski, BH. (2009). Chromium VI administration induces oxidative stress in hypothalamus and anterior pituitary gland from male rats. Toxicol Lett 185: 187–192. 10.1016/j.toxlet.2009.01.003.19167472
O'Brien, KO; Ru, Y. (2017). Iron status of North American pregnant women: An update on longitudinal data and gaps in knowledge from the United States and Canada [Review]. Am J Clin Nutr 106: 1647S-1654S. 10.3945/ajcn.117.155986.29070557
O'Brien, TJ; Ceryak, S; Patierno, S. R. (2003). Complexities of chromium carcinogenesis: role of cellular response, repair and recovery mechanisms [Review]. Mutat Res 533: 3–36. 10.1016/j.mrfmmm.2003.09.006.14643411
O'Brien, TJ; Ding, H; Suh, M; Thompson, CM; Parsons, BL; Harris, MA; Winkelman, WA; Wolf, JC; Hixon, JG; Schwartz, AM; Myers, MB; Haws, LC; Proctor, DM. (2013). Assessment of K-Ras mutant frequency and micronucleus incidence in the mouse duodenum following 90-days of exposure to Cr(VI) in drinking water. Mutat Res 754: 15–21. 10.1016/j.mrgentox.2013.03.008.23583686
O'Flaherty, EJ. (1993). A pharmacokinetic model for chromium. Toxicol Lett 68: 145–158. 10.1016/0378-4274(93)90127-J.8516761
O'Flaherty, EJ. (1996). A physiologically based model of chromium kinetics in the rat. Toxicol Appl Pharmacol 138: 54–64. 10.1006/taap.1996.0097.8658513
O'Flaherty, EJ; Kerger, BD; Hays, SM; Paustenbach, DJ. (2001). A physiologically based model for the ingestion of chromium(III) and chromium(VI) by humans. Toxicol Sci 60: 196–213. 10.1093/toxsci/60.2.196.11248132
O'Flaherty, EJ; Radike, MJ. (1991). Pharmacokinetic modeling of trivalent and hexavalent chromium based on ingestion and inhalation of soluble chromium compounds. (AL-TR-1991–0162). Wright-Patterson AFB, Ohio: Armstrong Laboratory. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=ADA256238.
O'Hara, KA; Klei, LR; Barchowsky, A. (2003). Selective activation of Src family kinases and JNK by low levels of chromium(VI). Toxicol Appl Pharmacol 190: 214–223. 10.1016/S0041-008X(03)00188-1.12902192
O'Neil, M; Heckelman, P; Koch, C. (2006). Chromium and compounds. In The Merck index. Whitehouse Station, NJ: Merck & Co. Inc.
O’Hara, KA; Klei, LR; Vaghjiani, RJ; Barchowsky, A. (2004). Selective signaling pathways for chromium(VI) induced patterns of transcription factor binding in exposed airway epithelial cells [Abstract]. Toxicologist 78: 239.
OAQPS (EPA Office of Air Quality Planning and Standards). (2012). Residual risk assessment for the chromic acid anodizing, decorative chromium electroplating, and hard chromium electroplating source categories. Research Triangle Park, NC: U.S. Environmental Protection Agency.
Ochieng, J; Chaudhuri, G. (2010). Cystatin superfamily [Review]. J Health Care Poor Underserved 21: 51–70. 10.1353/hpu.0.0257.20173285
OECD (Organisation for Economic Co-operation and Development). (2016a). Test no. 474: Mammalian erythrocyte micronucleus test [Standard]. In OECD guidelines for the testing of chemicals Section 4, health effects. Paris, France: OECD Publishing. 10.1787/9789264264762-en.
OECD (Organisation for Economic Co-operation and Development). (2016b). Test no. 478: Rodent dominant lethal test. In OECD guidelines for the testing of chemicals, Section 4: Health effects. Paris, France. 10.1787/9789264264823-en.
OECD (Organisation for Economic Co-operation and Development). (2020). Test no. 488: Transgenic rodent somatic and germ cell gene mutation assays. In OECD Guidelines for the Testing of Chemicals, Section 4: Health Effects. Paris, France. 10.1787/9789264203907-en.
Ohyama, W; Gonda, M; Miyajima, H; Kondo, K; Noguchi, T; Yoshida, J; Hatakeyama, S; Watabe, E; Ueno, Y; Hayashi, M; Tokumitsu, T. (2002). Collaborative validation study of the in vivo micronucleus test using mouse colonic epithelial cells. Mutat Res 518: 39–45. 10.1016/s1383-5718(02)00061-x.12063065
Okada, E; Fujiishi, Y; Narumi, K; Kado, S; Ohyama, W. (2019). Evaluation of a 28-day repeated-dose micronucleus test in rat glandular stomach, colon, and liver using gastrointestinal tract-targeted genotoxic-carcinogens and non-carcinogens. Mutat Res 844: 62–68. 10.1016/j.mrgentox.2019.05.008.
Olaguibel, JM; Basomba, A. (1989). Occupational asthma induced by chromium salts [Review]. Allergol Immunopathol 17: 133–136.
Oregon DEQ (Oregon Department of Environmental Quality). (2014). Update: Former Ken Foster Farm cleanup in Sherwood [Fact Sheet]. Portland, OR. http://www.deq.state.or.us/lq/cu/nwr/kenfoster/KenFosterFarmsFactSheet.pdf.
Oregon DEQ (Oregon Department of Environmental Quality). (2016a). Bullseye Glass area-wide soil sampling report. Portland, OR.
Oregon DEQ (Oregon Department of Environmental Quality). (2016b). Portland Metals air monitoring data. Portland, OR.
Oregon DEQ (Oregon Department of Environmental Quality). (2016c). Uroboros Glass area-wide soil sampling report. Portland, OR. http://www.oregon.gov/deq/FilterDocs/soilsamplingUro.pdf.
OSHA (Occupational Safety & Health Administration). (2006). Occupational exposure to hexavalent chromium. Final rule. Fed Reg 71: 10099–10385.
Ottenwaelder, H; Wiegand, HJ; Bolt, HM. (1988). Uptake of 51Cr(VI) by human erythrocytes: Evidence for a carrier-mediated transport mechanism. Sci Total Environ 71: 561–566. 10.1016/0048-9697(88)90237-9.3406724
Oze, C; Bird, DK; Fendorf, S. (2007). Genesis of hexavalent chromium from natural sources in soil and groundwater. Proc Natl Acad Sci USA 104: 6544–6549. 10.1073/pnas.0701085104.17420454
Oze, C; Fendorf, S; Bird, DK; Coleman, RG. (2004). Chrominium geochemistry of serpentine soils. International Geology Review 46: 97–126. 10.2747/0020-6814.46.2.97.
Pacyna, J; Nriagu, J. (1988). Atmospheric emissions of chromium from natural and anthropogenic sources. In JO Nriagu; E Nieboer (Eds.), Chromium in the natural and human environments (pp. 105–123). New York, NY: Wiley. https://www.wiley.com/en-us/Chromium+in+the+Natural+and+Human+Environments+-p-9780471856436.
Page, BJ; Loar, GW. (2004). Chromium compounds. In Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons.
Paixão, P; Bermejo, M; Hens, B; Tsume, Y; Dickens, J; Shedden, K; Salehi, N; Koenigsknecht, MJ; Baker, JR; Hasler, WL; Lionberger, R; Fan, J; Wysocki, J; Wen, B; Lee, A; Frances, A; Amidon, GE; Yu, A; Benninghoff, G; Löbenberg, R; Talattof, A; Sun, D; Amidon, GL. (2018). Gastric emptying and intestinal appearance of nonabsorbable drugs phenol red and paromomycin in human subjects: A multi-compartment stomach approach. Eur J Pharm Biopharm 129: 162–174. 10.1016/j.ejpb.2018.05.033.29857136
Pan, CH; Jeng, HA; Lai, CH. (2017). Biomarkers of oxidative stress in electroplating workers exposed to hexavalent chromium. J Expo Sci Environ Epidemiol 28: 76–83. 10.1038/jes.2016.85.28120834
Paone, P; Cani, PD. (2020). Mucus barrier, mucins and gut microbiota: The expected slimy partners? [Review]. Gut 69: 2232–2243. 10.1136/gutjnl-2020-322260.32917747
Park, S; Zhang, X; Li, C; Yin, C; Li, J; Fallon, JT; Huang, W; Xu, D. (2017). Single-cell RNA sequencing reveals an altered gene expression pattern as a result of CRISPR/cas9-mediated deletion of Gene 33/Mig6 and chronic exposure to hexavalent chromium in human lung epithelial cells. Toxicol Appl Pharmacol 330: 30–39. 10.1016/j.taap.2017.07.003.28688920
Parker, D; Turk, JL; Drossler, K. (1984). Comparison of DNFB and K2Cr2O7 'flare-up' reactions in the guinea pig. International Arch Allergy Appl Immunol 73: 123–128. 10.1159/000233451.
Parrott, N; Lukacova, V; Fraczkiewicz, G; Bolger, MB. (2009). Predicting pharmacokinetics of drugs using physiologically based modeling--application to food effects [Review]. AAPS J 11: 45–53. 10.1208/s12248-008-9079-7.19184451
Parsons, BL; Marchant-Miros, KE; Delongchamp, RR; Verkler, TL; Patterson, TA; Mckinzie, PB; Kim, LT. (2010). ACB-PCR quantification of K-RAS codon 12 GAT and GTT mutant fraction in colon tumor and non-tumor tissue. Cancer Invest 28: 364–375. 10.3109/07357901003630975.20307197
Pascal, LE; Tessier, DM. (2004). Cytotoxicity of chromium and manganese to lung epithelial cells in vitro. Toxicol Lett 147: 143–151. 10.1016/j.toxlet.2003.11.004.14757318
Patlolla, AK; Barnes, C; Hackett, D; Tchounwou, PB. (2009). Potassium dichromate induced cytotoxicity, genotoxicity and oxidative stress in human liver carcinoma (HepG2) cells. Int J Environ Res Public Health 6: 643–653. 10.3390/ijerph6020643.19440407
Paustenbach, DJ; Hays, SM; Brien, BA; Dodge, DG; Kerger, BD. (1996). Observation of steady state in blood and urine following human ingestion of hexavalent chromium in drinking water. J Toxicol Environ Health 49: 453–461. 10.1080/009841096160682.8968407
Pellerin, C; Booker, SM. (2000). Reflections on hexavalent chromium: Health hazards of an industrial heavyweight. Environ Health Perspect 108: a402–a407. 10.1289/ehp.108-a402.11017901
Peng, N; Zhao, X. (2014). Comparison of K-ras mutations in lung, colorectal and gastric cancer. Oncol Lett 8: 561–565. 10.3892/ol.2014.2205.25013470
Peng, Y; Hu, J; Li, Y; Zhang, B; Liu, W; Li, H; Zhang, H; Hu, C; Chen, X; Xia, W; Lu, S; Xu, S. (2018). Exposure to chromium during pregnancy and longitudinally assessed fetal growth: Findings from a prospective cohort. Environ Int 121: 375–382. 10.1016/j.envint.2018.09.003.30245360
Peters, S; Vermeulen, R; Portengen, L; Olsson, A; Kendzia, B; Vincent, R; Savary, B; Lavoué, J; Cavallo, D; Cattaneo, A; Mirabelli, D; Plato, N; Fevotte, J; Pesch, B; Brüning, T; Straif, K; Kromhout, H. (2016). SYN-JEM: A Quantitative Job-Exposure Matrix for Five Lung Carcinogens. Ann Occup Hyg 60: 795–811. 10.1093/annhyg/mew034.27286764
Peterson-Roth, E; Reynolds, M; Quievryn, G; Zhitkovich, A. (2005). Mismatch repair proteins are activators of toxic responses to chromium-DNA damage. Mol Cell Biol 25: 3596–3607. 10.1128/MCB.25.9.3596-3607.2005.15831465
Petrilli, FL; De Flora, S. (1982). Interpretations on chromium mutagenicity and carcinogenicity. In M Sorsa; H Vainio (Eds.), Mutagens in our environment: Proceedings of the twelfth annual meeting of the European Environmental Mutagen Society (pp. 453–464). New York, NY: A. R. Liss.
Petrilli, FL; Rossi, GA; Camoirano, A; Romano, M; Serra, D; Bennicelli, C; De Flora, A; De Flora, S. (1986). Metabolic reduction of chromium by alveolar macrophages and its relationships to cigarette smoke. J Clin Invest 77: 1917–1924. 10.1172/JCI112520.2423559
PHS (U.S. Public Health Service). (1953). Health of workers in chromate producing industry. (No. 192). Washington, DC.
Pilat, M; Pegnam, R. (2006). Particle emissions from chrome plating. Aerosol Sci Technol 40: 639–648.
Poljsak, B; Gazdag, Z; Jenko-Brinovec, S; Fujs, S; Pesti, M; Bélagyi, J; Plesnicar, S; Raspor, P. (2005). Pro-oxidative vs antioxidative properties of ascorbic acid in chromium(VI)-induced damage: an in vivo and in vitro approach. J Appl Toxicol 25: 535–548. 10.1002/jat.1093.16092082
Pool-Zobel, BL; Lotzmann, N; Knoll, M; Kuchenmeister, F; Lambertz, R; Leucht, U; Schröder, HG; Schmezer, P. (1994). Detection of genotoxic effects in human gastric and nasal mucosa cells isolated from biopsy samples. Environ Mol Mutagen 24: 23–45. 10.1002/em.2850240105.7519553
Popp, W; Vahrenholz, C; Schmieding, W; Krewet, E; Norpoth, K. (1991). Investigations of the frequency of DNA strand breakage and cross-linking and of sister chromatid exchange in the lymphocytes of electric welders exposed to chromium- and nickel-containing fumes. Int Arch Occup Environ Health 63: 115–120. 10.1007/BF00379074.1889880
Popper, HH; Grygar, E; Ingolic, E; Wawschinek, O. (1993). Cytotoxicity of chromium-III and chromium-VI compounds. I. In vitro studies using different cell culture systems. Inhal Toxicol 5: 345–369. 10.3109/08958379308998392.
Potten, CS; Booth, C; Pritchard, DM. (1997). The intestinal epithelial stem cell: the mucosal governor [Review]. Int J Exp Pathol 78: 219–243. 10.1046/j.1365-2613.1997.280362.x.9505935
Potten, CS; Gandara, R; Mahida, YR; Loeffler, M; Wright, NA. (2009). The stem cells of small intestinal crypts: where are they? Cell Prolif 42: 731–750. 10.1111/j.1365-2184.2009.00642.x.19788585
Pournourmohammadi, S; Khazaelp, P; Eslamizad, S; Tajvar, A; Mohammadirad, A; Abdollahi, M. (2008). Study on the oxidative stress status among cement plant workers. Hum Exp Toxicol 27: 463–469. 10.1177/0960327108094956.18784198
Proctor, DM; Panko, JP; Liebig, EW; Paustenbach, DJ. (2004). Estimating historical occupational exposure to airborne hexavalent chromium in a chromate production plant: 1940--1972. J Occup Environ Hyg 1: 752–767. 10.1080/15459620490523294.15673096
Proctor, DM; Suh, M; Aylward, LL; Kirman, CR; Harris, MA; Thompson, CM; Gürleyük, H; Gerads, R; Haws, LC; Hays, SM. (2012). Hexavalent chromium reduction kinetics in rodent stomach contents. Chemosphere 89: 487–493. 10.1016/j.chemosphere.2012.04.065.22682893
Proctor, DM; Suh, M; Mittal, L, iz; Hirsch, S; Salgado, RV; Bartlett, C; Van Landingham, C; Rohr, A; Crump, K. (2016). Inhalation cancer risk assessment of hexavalent chromium based on updated mortality for Painesville chromate production workers. J Expo Sci Environ Epidemiol 26: 224–231. 10.1038/jes.2015.77.26669850
Pukkala, E; Martinsen, J; Lynge, E; Gunnarsdottir, H; Sparén, P; Tryggvadottir, L; Weiderpass, E; Kjaerheim, K. (2009). Occupation and cancer - follow-up of 15 million people in five Nordic countries. Acta Oncol 48: 646–790. 10.1080/02841860902913546.19925375
Pye, W. (1885). II. The Local Lesions caused by the Alkaline Salts of Chromic Acid. Ann Surg 1: 303–308.
Qayyum, S; Ara, A; Usmani, JA. (2012). Effect of nickel and chromium exposure on buccal cells of electroplaters. Toxicol Ind Health 28: 74–82. 10.1177/0748233711407237.21636684
Qian, Q, in; Li, P; Wang, T; Zhang, J, i; Yu, S; Chen, T; Yan, L, ei; Song, Y; Liu, X; Gu, Y; Wang, Y, un; Jia, G. (2013). Alteration of Th1/Th2/Th17 cytokine profile and humoral immune responses associated with chromate exposure. Occup Environ Med 70: 697–702. 10.1136/oemed-2013-101421.23811143
Qin, Q; Xie, H; Wise, SS; Browning, CL; Thompson, KN; Holmes, AL; Wise, JP. (2014). Homologous recombination repair signaling in chemical carcinogenesis: prolonged particulate hexavalent chromium exposure suppresses the rad51 response in human lung cells. Toxicol Sci 142: 117–125. 10.1093/toxsci/kfu175.25173789
Quansah, R; Jaakkola, JJ. (2009). Paternal and maternal exposure to welding fumes and metal dusts or fumes and adverse pregnancy outcomes. Int Arch Occup Environ Health 82: 529–537. 10.1007/s00420-008-0349-6.18820944
Quante, M; Tu, SP; Tomita, H; Gonda, T; Wang, SS; Takashi, S; Baik, GH; Shibata, W; Diprete, B; Betz, KS; Friedman, R; Varro, A; Tycko, B; Wang, TC. (2011). Bone marrow-derived myofibroblasts contribute to the mesenchymal stem cell niche and promote tumor growth. Cancer Cell 19: 257–272. 10.1016/j.ccr.2011.01.020.21316604
Quante, M; Varga, J; Wang, TC; Greten, FR. (2013). The gastrointestinal tumor microenvironment [Review]. Gastroenterology 145: 63–78. 10.1053/j.gastro.2013.03.052.23583733
Quante, M; Wang, TC. (2008). Inflammation and stem cells in gastrointestinal carcinogenesis [Review]. Physiology (Bethesda) 23: 350–359. 10.1152/physiol.00031.2008.19074742
Quante, M; Wang, TC. (2009). Stem cells in gastroenterology and hepatology. Nat Rev Gastroenterol Hepatol 6: 724–737. 10.1038/nrgastro.2009.195.19884893
Quievryn, G; Goulart, M; Messer, J; Zhitkovich, A. (2001). Reduction of Cr (VI) by cysteine: Significance in human lymphocytes and formation of DNA damage in reactions with variable reduction rates. Mol Cell Biochem 222: 107–118. 10.1023/A:1017923609175.11678591
Quievryn, G; Messer, J; Zhitkovich, A. (2002). Carcinogenic chromium(VI) induces cross-linking of vitamin C to DNA in vitro and in human lung A549 cells. Biochemistry 41: 3156–3167. 10.1021/bi011942z.11863455
Quievryn, G; Messer, J; Zhitkovich, A. (2006). Lower mutagenicity but higher stability of Cr-DNA adducts formed during gradual chromate activation with ascorbate. Carcinogenesis 27: 2316–2321. 10.1093/carcin/bgl076.16714765
Quievryn, G; Peterson, E; Messer, J; Zhitkovich, A. (2003). Genotoxicity and mutagenicity of chromium(VI)/ascorbate-generated DNA adducts in human and bacterial cells. Biochemistry 42: 1062–1070. 10.1021/bi0271547.12549927
Quinteros, FA; Machiavelli, LI; Miler, EA; Cabilla, JP; Duvilanski, BH. (2008). Mechanisms of chromium (VI)-induced apoptosis in anterior pituitary cells. Toxicology 249: 109–115. 10.1016/j.tox.2008.04.012.18547707
Quinteros, FA; Poliandri, AH; Machiavelli, LI; Cabilla, JP; Duvilanski, BH. (2007). In vivo and in vitro effects of chromium VI on anterior pituitary hormone release and cell viability. Toxicol Appl Pharmacol 218: 79–87. 10.1016/j.taap.2006.10.017.17141818
Qureshi, IZ; Mahmood, T. (2010). Prospective role of ascorbic acid (vitamin C) in attenuating hexavalent chromium-induced functional and cellular damage in rat thyroid. Toxicol Ind Health 26: 349–359. 10.1177/0748233710371109.20504825
Radke, EG; Glenn, B; Galizia, A; Persad, A; Nachman, R; Bateson, T; Wright, JM; Navas-Acien, A; Arroyave, WD; Puett, RC; Harville, EW; Pollack, AZ; Burns, JS; Lynch, CD; Sagiv, SK; Stein, C; Cooper, GS. (2019). Development of outcome-specific criteria for study evaluation in systematic reviews of epidemiology studies. Environ Int 130: 104884. 10.1016/j.envint.2019.05.078.31299560
Radtke, F; Clevers, H. (2005). Self-renewal and cancer of the gut: two sides of a coin [Review]. Science 307: 1904–1909. 10.1126/science.1104815.15790842
Rafael, AI; Almeida, A; Santos, P; Parreira, I; Madeira, VM; Alves, R; Cabrita, AM; Alpoim, MC. (2007). A role for transforming growth factor-beta apoptotic signaling pathway in liver injury induced by ingestion of water contaminated with high levels of Cr(VI). Toxicol Appl Pharmacol 224: 163–173. 10.1016/j.taap.2007.07.004.17692352
Rager, JE; Ring, CL; Fry, RC; Suh, M; Proctor, DM; Haws, LC; Harris, MA; Thompson, CM. (2017). High-throughput screening data interpretation in the context of in vivo transcriptomic responses to oral Cr(VI) exposure. Toxicol Sci 158: 199–212. 10.1093/toxsci/kfx085.28472532
Rager, JE; Suh, M; Chappell, GA; Thompson, CM; Proctor, DM. (2019). Review of transcriptomic responses to hexavalent chromium exposure in lung cells supports a role of epigenetic mediators in carcinogenesis [Review]. Toxicol Lett 305: 40–50. 10.1016/j.toxlet.2019.01.011.30690063
Rahman, MM; Abe, SK; Rahman, MS; Kanda, M; Narita, S; Bilano, V; Ota, E; Gilmour, S; Shibuya, K. (2016). Maternal anemia and risk of adverse birth and health outcomes in low- and middle-income countries: Systematic review and meta-analysis [Review]. Am J Clin Nutr 103: 495–504. 10.3945/ajcn.115.107896.26739036
Rao, MV; Chawla, SL; Sharma, SR. (2009). Protective role of vitamin E on nickel and/or chromium induced oxidative stress in the mouse ovary. Food Chem Toxicol 47: 1368–1371. 10.1016/j.fct.2009.03.018.19306907
Rasool, M; Zaigham, K; Malik, A; Naseer, MI; Umm-E-Habiba, MI; Manan, A; Qazi, MH; Asif, M. (2014). Potential reproductive health effects and oxidative stress associated with exposure to potassium dichromate (K2Cr2O7) and magnesium sulphate (MgSO4) in male mice. Pakistan Journal of Medical Sciences online 30: 819–823.
Rawla, P; Barsouk, A. (2019). Epidemiology of gastric cancer: Global trends, risk factors and prevention [Review]. Prz Gastroenterol 14: 26–38. 10.5114/pg.2018.80001.30944675
Reddy, M; Yang, R; Clewell, HJ; Andersen, ME. (2005). Physiologically based pharmacokinetic modeling: Science and applications. Hoboken, New Jersey: John Wiley & Sons.
Remy, LL; Byers, V; Clay, T. (2017). Reproductive outcomes after non-occupational exposure to hexavalent chromium, Willits California, 1983–2014. Environ Health 16: 18. 10.1186/s12940-017-0222-8.28264679
Ren, K; Li, Y; Lu, H; Li, Z; Han, X. (2017). miR-3940–5p Functions as a Tumor Suppressor in Non-Small Cell Lung Cancer Cells by Targeting Cyclin D1 and Ubiquitin Specific Peptidase-28. Translational Oncology 10: 80–89. 10.1016/j.tranon.2016.11.004.27988424
Ren, R; Li, Z; Zhang, Z. (2003). [Investigation on the effect of occupational chromium on workers' fertility]. Zhongguo Gonggong Weisheng Guanli/Chinese Journal of Public Health Management (1): 82–83.
Reynolds, M; Armknecht, S; Johnston, T; Zhitkovich, A. (2012). Undetectable role of oxidative DNA damage in cell cycle, cytotoxic and clastogenic effects of Cr(VI) in human lung cells with restored ascorbate levels. Mutagenesis 27: 437–443. 10.1093/mutage/ger095.22241526
Reynolds, M; Zhitkovich, A. (2007). Cellular vitamin C increases chromate toxicity via a death program requiring mismatch repair but not p53. Carcinogenesis 28: 1613–1620. 10.1093/carcin/bgm031.17301063
Richardson, DB; Langholz, B. (2012). Background stratified Poisson regression analysis of cohort data. Radiat Environ Biophys 51: 15–22. 10.1007/s00411-011-0394-5.22193911
Ritchie, RF; Palomaki, GE; Neveux, LM; Navolotskaia, O; Ledue, TB; Craig, WY. (2004). Reference distributions for complement proteins C3 and C4: A practical, simple and clinically relevant approach in a large cohort. J Clin Lab Anal 18: 1–8. 10.1002/jcla.10100.14730550
Riva, L; Pandiri, AR; Li, YR; Droop, A; Hewinson, J; Quail, MA; Iyer, V; Shepherd, R; Herbert, RA; Campbell, PJ; Sills, RC; Alexandrov, LB; Balmain, A; Adams, DJ. (2020). The mutational signature profile of known and suspected human carcinogens in mice. Nat Genet 52: 1189–1197. 10.1038/s41588-020-0692-4.32989322
Rothman, K. (2010). Curbing type I and type II errors. Eur J Epidemiol 25: 223–224. 10.1007/s10654-010-9437-5.20232112
Royle, H. (1975). Toxicity of chromic acid in the chromium plating industry(2). Environ Res 10: 141–163. 10.1016/0013-9351(75)90079-1.1175577
Rudnykh, AA; Zasukhina, GD. (1985). DNA repair synthesis in lymphocytes of people contacting chromium compounds in industry. Cytology and Genetics 19: 68–69.
Russell, TL; Berardi, RR; Barnett, JL; Dermentzoglou, LC; Jarvenpaa, KM; Schmaltz, SP; Dressman, JB. (1993). Upper gastrointestinal pH in seventy-nine healthy, elderly, North American men and women. Pharm Res 10: 187–196. 10.1023/A:1018970323716.8456064
Russo, P; Catassi, A; Cesario, A; Imperatori, A; Rotolo, N; Fini, M; Granone, P; Dominioni, L. (2005). Molecular mechanisms of hexavalent chromium-induced apoptosis in human bronchoalveolar cells. Am J Respir Cell Mol Biol 33: 589–600. 10.1165/rcmb.2005-0213OC.16166740
Saleh, FY; Parkerton, TF; Lewis, RV; Huang, JH; Dickson, KL. (1989). Kinetics of chromium transformations in the environment. Sci Total Environ 86: 25–41.2602935
Salnikow, K; Zhitkovich, A. (2008). Genetic and epigenetic mechanisms in metal carcinogenesis and cocarcinogenesis: Nickel, arsenic, and chromium [Review]. Chem Res Toxicol 21: 28–44. 10.1021/tx700198a.17970581
Saloga, J; Knop, J; Kolde, G. (1988). Ultrastructural cytochemical visualization of chromium in the skin of sensitized guinea pigs. Arch Dermatol Res 280: 214–219.3233013
Samuel, JB; Stanley, JA; Roopha, DP; Vengatesh, G; Anbalagan, J; Banu, SK; Aruldhas, MM. (2011). Lactational hexavalent chromium exposure-induced oxidative stress in rat uterus is associated with delayed puberty and impaired gonadotropin levels. Hum Exp Toxicol 30: 91–101. 10.1177/0960327110364638.20203132
Samuel, JB; Stanley, JA; Sekar, P; Princess, RA; Sebastian, MS; Aruldhas, MM. (2012a). Persistent hexavalent chromium exposure impaired the pubertal development and ovarian histoarchitecture in wistar rat offspring. Environ Toxicol 29: 814–828. 10.1002/tox.21810.22936640
Samuel, JB; Stanley, JA; Vengatesh, G; Princess, RA; Muthusami, S; Roopha, DP; Suthagar, E; Kumar, KM; Sebastian, MS; Aruldhas, MM. (2012b). Ameliorative effect of vitamin C on hexavalent chromium-induced delay in sexual maturation and oxidative stress in developing Wistar rat ovary and uterus. Toxicol Ind Health 28: 720–733. 10.1177/0748233711422728.22033423
Sánchez-Martín, FJ; Fan, Y; Carreira, V; Ovesen, JL; Vonhandorf, A; Xia, Y; Puga, A. (2015). Long-term coexposure to hexavalent chromium and B[a]P causes tissue-specific differential biological effects in liver and gastrointestinal tract of mice. Toxicol Sci 146: 52–64. 10.1093/toxsci/kfv070.25820237
Sánchez, LM; Lewicki, M; De Lucca, RC; Ubios, ÁM. (2015). Impairment of bony crypt development associated with hexavalent chromium exposure during tooth eruption. Acta Odontol Latinoam 28: 203–209.27095619
Sánchez, LM; Ubios, ÁM. (2020). Alterations in odontogenesis and tooth eruption resulting from exposure to hexavalent chromium in suckling animals. Int J Paediatr Dent 30: 35–41. 10.1111/ipd.12573.31461794
Sánchez, LM; Ubios, ÁM. (2021). Hexavalent chromium exposure alters bone remodeling in the developing tooth alveolus and delays tooth eruption. 34: 91–97. 10.54589/aol.34/2/091.
Saraswathy, CP; Usharani, MV. (2007). Monitoring of cellular enzymes in the serum of electroplating workers at Coimbatore. J Environ Biol 28: 287–290.17915767
Sarkar, D; Sharma, A; Talukder, G. (1993). Differential protection of chlorophyllin against clastogenic effects of chromium and chlordane in mouse bone marrow in vivo. Mutat Res 301: 33–38. 10.1016/0165-7992(93)90053-X.7677941
Sarkar, D; Sharma, A; Talukder, G. (1996). Protection afforded by crude spinach-beet leaf extract and equivalent amounts of chlorophyll and chlorophyllin against clastogenic effects of potassium dichromate in mice in vivo. Int J Pharmacogn 34: 58–63. 10.1076/phbi.34.1.58.13174.
Sarlinova, M; Majerova, L; Matakova, T; Musak, L; Slovakova, P; Skereňová, M; Kavcová, E; Halašová, E. (2015). Polymorphisms of DNA repair genes and lung cancer in chromium exposure. Adv Exp Med Biol 833: 1–8. 10.1007/5584_2014_82.25300687
Sarto, F; Cominato, I; Bianchi, V; Levis, AG. (1982). Increased incidence of chromosomal aberrations and sister chromatid exchanges in workers exposed to chromic acid (CrO3) in electroplating factories. Carcinogenesis 3: 1011–1016. 10.1093/carcin/3.9.1011.7139855
Sarto, F; Tomanin, R; Giacomelli, L; Iannini, G; Cupiraggi, AR. (1990). The micronucleus assay in human exfoliated cells of the nose and mouth: Application to occupational exposures to chromic acid and ethylene oxide. Mutat Res 244: 345–351. 10.1016/0165-7992(90)90083-V.2385249
Sasso, AF; Schlosser, PM. (2015). An evaluation of in vivo models for toxicokinetics of hexavalent chromium in the stomach. Toxicol Appl Pharmacol 287: 293–298. 10.1016/j.taap.2015.06.016.26123277
Savitz, DA. (1993). Is statistical significance testing useful in interpreting data? [Review]. Reprod Toxicol 7: 95–100.
Sawicka, E; Długosz, A. (2017). The role of 17β-estradiol metabolites in chromium-induced oxidative stress. Advances in Clinical and Experimental Medicine 26: 215–221. 10.17219/acem/62217.28791837
Sazakli, E; Villanueva, CM; Kogevinas, M; Maltezis, K; Mouzaki, A; Leotsinidis, M. (2014). Chromium in Drinking Water: Association with Biomarkers of Exposure and Effect. Int J Environ Res Public Health 11: 10125–10145. 10.3390/ijerph111010125.25268509
SCAQMD (South Coast Air Quality Management District). (2016). Summary of efforts in paramount: significant improvements since October 2016.
Schiestl, RH; Aubrecht, J; Khogali, F; Carls, N. (1997). Carcinogens induce reversion of the mouse pink-eyed unstable mutation. Proc Natl Acad Sci USA 94: 4576–4581. 10.1073/pnas.94.9.4576.9114032
Schlesinger, RB; Lippmann, M. (1978). Selective particle deposition and bronchogenic carcinoma. Environ Res 15: 424–431.679903
Schlosser, PM; Sasso, AF. (2014). A revised model of ex-vivo reduction of hexavalent chromium in human and rodent gastric juices. Toxicol Appl Pharmacol 280: 352–361. 10.1016/j.taap.2014.08.010.25151221
Schneeberger, HW; Forck, G. (1974). Experimental chromium allergy of animals: The influence of valences and chemical properties of chromium ions. 249: 71–81.
Schroeder, WH; Dobson, M; Kane, DM; Johnson, ND. (1987). Toxic trace elements associated with airborne particulate matter: A review [Review]. J Air Waste Manag Assoc 37: 1267–1285. 10.1080/08940630.1987.10466321.
Schwitalla, S; Fingerle, AA; Cammareri, P; Nebelsiek, T; Göktuna, SI; Ziegler, PK; Canli, O; Heijmans, J; Huels, DJ; Moreaux, G; Rupec, RA; Gerhard, M; Schmid, R; Barker, N; Clevers, H; Lang, R; Neumann, J; Kirchner, T; Taketo, MM; van den Brink, GR; Sansom, OJ; Arkan, MC; Greten, FR. (2013). Intestinal tumorigenesis initiated by dedifferentiation and acquisition of stem-cell-like properties. Cell 152: 25–38. 10.1016/j.cell.2012.12.012.23273993
Scott, P; Anderson, K; Singhania, M; Cormier, R. (2020). Cystic Fibrosis, CFTR, and Colorectal Cancer [Review]. International Journal of Molecular Sciences 21. 10.3390/ijms21082891.
Sedman, RM; Beaumont, J; Mcdonald, TA; Reynolds, S; Krowech, G; Howd, R. (2006). Review of the evidence regarding the carcinogenicity of hexavalent chromium in drinking water [Review]. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 24: 155–182. 10.1080/10590500600614337.16690539
Sekihashi, K; Sasaki, T; Yamamoto, A; Kawamura, K; Ikka, T; Tsuda, S; Sasaki, YF. (2001). A comparison of intraperitoneal and oral gavage administration in comet assay in mouse eight organs. Mutat Res 493: 39–54. 10.1016/S1383-5718(01)00157-7.11516714
Sellappa, S; Prathyumnan, S; Keyan, KS; Joseph, S; Vasudevan, BS; Sasikala, K. (2010). Evaluation of DNA damage induction and repair inhibition in welders exposed to hexavalent chromium. Asian Pac J Cancer Prev 11: 95–100.20593913
Sengupta, T; Chattopadhyay, D; Ghosh, N; Das, M; Chatterjee, GC. (1990). Effect of chromium administration on glutathione cycle of rat intestinal epithelial cells. Indian J Exp Biol 28: 1132–1135.2099328
Seoane, AI; Dulout, FN. (1999). Contribution to the validation of the anaphase-telophase test: Aneugenic and clastogenic effects of cadmium sulfate, potassium dichromate and nickel chloride in Chinese hamster ovary cells. Genet Mol Biol 22: 551–555.
Seoane, AI; Dulout, FN. (2001). Genotoxic ability of cadmium, chromium and nickel salts studied by kinetochore staining in the cytokinesis-blocked micronucleus assay. Mutat Res 490: 99–106. 10.1016/S1383-5718(00)00145-5.11342235
Seoane, AI; Güerci, AM; Dulout, FN. (2002). Malsegregation as a possible mechanism of aneuploidy induction by metal salts in MRC-5 human cells. Environ Mol Mutagen 40: 200–206. 10.1002/em.10110.12355554
Sharma, N; Chauhan, S; Varma, S. (2003). Fatal potassium dichromate ingestion [Letter]. J Postgrad Med 49: 286–287.
Sharma, P; Bihari, V; Agarwal, SK; Verma, V; Kesavachandran, CN; Pangtey, BS; Mathur, N; Singh, KP; Srivastava, M; Goel, SK. (2012). Groundwater contaminated with hexavalent chromium [Cr (VI)]: a health survey and clinical examination of community inhabitants (Kanpur, India). PLoS ONE 7: e47877. 10.1371/journal.pone.0047877.23112863
Sharma, S; Kelly, TK; Jones, PA. (2010). Epigenetics in cancer [Review]. Carcinogenesis 31: 27–36. 10.1093/carcin/bgp220.19752007
Shaw Environmental (Shaw Environmental, Inc). (2006). Final report. Industry profile, exposure profile, technological feasibility evaluation, and environmental impact for industries affected by a revised OSHA standard for hexavalent chromium (General industry, construction, and maritime sectors). (OSHA-H054A-2006–0064-2537). Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. https://www.regulations.gov/document?D=OSHA-H054A-2006-0064-2537.
Shaw, L; Shaw, D, on; Hardisty, M; Britz-Mckibbin, P; Verma, DK. (2020). Relationships between inhalable and total hexavalent chromium exposures in steel passivation, welding and electroplating operations of Ontario. Int J Hyg Environ Health 230: 113601. 10.1016/j.ijheh.2020.113601.32836071
Shi, H; Hudson, LG; Liu, KJ. (2004). Oxidative stress and apoptosis in metal ion-induced carcinogenesis [Review]. Free Radic Biol Med 37: 582–593. 10.1016/j.freeradbiomed.2004.03.012.15288116
Shih, GL; Brensinger, C; Katzka, DA; Metz, DC. (2003). Influence of age and gender on gastric acid secretion as estimated by integrated acidity in patients referred for 24-hour ambulatory pH monitoring. Am J Gastroenterol 98: 1713–1718. 10.1016/S0002-9270(03)00435-0.12907323
Shih, IM; Wang, TL; Traverso, G; Romans, K; Hamilton, SR; Ben-Sasson, S; Kinzler, KW; Vogelstein, B. (2001). Top-down morphogenesis of colorectal tumors. Proc Natl Acad Sci USA 98: 2640–2645. 10.1073/pnas.051629398.11226292
Shindo, Y; Toyoda, Y; Kawamura, K; Kurebe, M; Shimada, H; Hattori, C; Satake, S. (1989). Micronucleus test with potassium chromate(VI) administered intraperitoneally and orally to mice. Mutat Res 223: 403–406.2747727
Shobana, N; Aruldhas, MM; Tochhawng, L; Loganathan, A; Balaji, S; Kumar, MK; Banu, LAS; Navin, AK; Mayilvanan, C; Ilangovan, R; Balasubramanian, K. (2017). Transient gestational exposure to drinking water containing excess hexavalent chromium modifies insulin signaling in liver and skeletal muscle of rat progeny. Chem Biol Interact 277: 119–128. 10.1016/j.cbi.2017.09.003.28911802
Shobana, N; Kumar, MK; Navin, AK; Akbarsha, MA; Aruldhas, MM. (2020). Prenatal exposure to excess chromium attenuates transcription factors regulating expression of androgen and follicle stimulating hormone receptors in Sertoli cells of prepuberal rats. Chem Biol Interact 328: 109188. 10.1016/j.cbi.2020.109188.32679048
Shoeb, M; Kodali, VK; Farris, BY; Bishop, LM; Meighan, TG; Salmen, R; Eye, T; Friend, S; Schwegler-Berry, D; Roberts, JR; Zeidler-Erdely, PC; Erdely, A; Antonini, JM. (2017). Oxidative stress, DNA methylation, and telomere length changes in peripheral blood mononuclear cells after pulmonary exposure to metal-rich welding nanoparticles. NanoImpact 5: 61–69. 10.1016/j.impact.2017.01.001.30734006
Shrivastava, R; Srivastava, S; Upreti, RK; Chaturvedi, UC. (2005a). Effects of dengue virus infection on peripheral blood cells of mice exposed to hexavalent chromium with drinking water. Indian J Med Res 122: 111–119.16177467
Shrivastava, R; Upreti, RK; Chaturvedi, UC. (2003). Various cells of the immune system and intestine differ in their capacity to reduce hexavalent chromium. FEMS Immunol Med Microbiol 38: 65–70.12900057
Shrivastava, R; Upreti, RK; Chaturvedi, UC. (2005b). Effects of dengue virus infection on the spleen of male mice given hexavalent chromium with drinking water. Toxicol Mech Meth 15: 323–329. 10.1080/153765291009732.
Shubin, AV; Demidyuk, IV; Komissarov, AA; Rafieva, LM; Kostrov, SV. (2016). Cytoplasmic vacuolization in cell death and survival [Review]. Onct 7: 55863–55889. 10.18632/oncotarget.10150.
Shumilla, JA; Barchowsky, A. (1999). Inhibition of protein synthesis by chromium(VI) differentially affects expression of urokinase and its receptor in human type II pneumocytes. Toxicol Appl Pharmacol 158: 288–295. 10.1006/taap.1999.8704.10438662
Siegenthaler, U; Laine, A; Polak, L. (1983). Studies on contact sensitivity to chromium in the guinea pig The role of valence in the formation of the antigenic determinant. J Invest Dermatol 80: 44–47.6184422
Singh, CBP; Sharma, A; Talukder, G. (1990). Effects of chromium on cellular systems in animals. Nucleus 33: 84–106.
Singhal, VK; Deswal, BS; Singh, BN. (2015). Study of skin and mucous membrane disorders among workers engaged in the sodium dichromate manufacturing industry and chrome plating industry. Indian J Occup Environ Med 19: 129–133. 10.4103/0019-5278.173994.26957809
Sitalakshmi, R; Saikumar, P; Jeyachandran, P; Manoharan, P; Thangavel, P; Thomas, J. (2016). Civil construction work: The unseen contributor to the occupational and global disease burden. Indian J Occup Environ Med 20: 103–108. 10.4103/0019-5278.197542.28194084
Sivakumar, KK; Stanley, JA; Arosh, JA; Pepling, ME; Burghardt, RC; Banu, SK. (2014). Prenatal exposure to chromium induces early reproductive senescence by increasing germ cell apoptosis and advancing germ cell cyst breakdown in the F1 offspring. Dev Biol 388: 22–34. 10.1016/j.ydbio.2014.02.003.24530425
Sivakumar, KK; Stanley, JA; Behlen, JC; Wuri, L; Dutta, S; Wu, J; Arosh, JA; Banu, SK. (2022). Inhibition of Sirtuin-1 hyperacetylates p53 and abrogates Sirtuin-1-p53 interaction in Cr(VI)-induced apoptosis in the ovary. Reprod Toxicol 109: 121–134. 10.1016/j.reprotox.2022.03.007.35307491
Smith, AH. (2008). Hexavalent chromium, yellow water, and cancer: a convoluted saga.[comment] [Letter]. Epidemiology 19: 24–26.18091414
Smith, DB; Cannon, WF; Woodruff, LG; Solano, F; Kilburn, JE; Fey, DL. (2013). Geochemical and mineralogical data for soils of the conterminous United States. (Data Series 801). Reston, VA: U.S. Department of the Interior, U.S. Geological Survey. http://pubs.usgs.gov/ds/801/.
Smith, MT; Guyton, KZ; Gibbons, CF; Fritz, JM; Portier, CJ; Rusyn, I; Demarini, DM; Caldwell, JC; Kavlock, RJ; Lambert, PF; Hecht, SS; Bucher, J. R.; Stewart, BW; Baan, RA; Cogliano, VJ; Straif, K. (2016). Key characteristics of carcinogens as a basis for organizing data on mechanisms of carcinogenesis [Review]. Environ Health Perspect 124: 713–721. 10.1289/ehp.1509912.26600562
Snow, ET; Xu, LS. (1991). Chromium(III) bound to DNA templates promotes increased polymerase processivity and decreased fidelity during replication in vitro. Biochemistry 30: 11238–11245.1958661
Snyder, CA; Udasin, I; Waterman, SJ; Toioli, E; Gochfeld, M. (1996). Reduced IL-6 levels among individuals in Hudson County, New Jersey, an area contaminated with chromium. Arch Environ Health 51: 26–28. 10.1080/00039896.1996.9935989.8629859
Snyder, CA; Valle, CD. (1991). Immune function assays as indicators of chromate exposure. Environ Health Perspect 92: 83–86. 10.1289/ehp.919283.1834456
Soares, ME; Vieira, E; Bastos, M. (2010). Chromium speciation analysis in bread samples. J Agric Food Chem 58: 1366–1370. 10.1021/jf903118v.19904987
Sobaszek, A; Edme, JL; Boulenguez, C; Shirali, P; Mereau, M; Robin, H; Haguenoer, JM. (1998). Respiratory symptoms and pulmonary function among stainless steel welders. J Occup Environ Med 40: 223–229.9531093
Song, Y; Zhang, J; Yu, S; Wang, T; Cui, X; Du, X; Jia, G. (2012). Effects of chronic chromium(vi) exposure on blood element homeostasis: an epidemiological study. Metallomics 4: 463–472. 10.1039/c2mt20051a.22522219
Sorahan, T; Burges, DCL; Waterhouse, JAH. (1987). A mortality study of nickel/chromium platers. Br J Ind Med 44: 250–258.3567099
Soudani, N; Bouaziz, H; Sefi, M; Chtourou, Y; Boudawara, T; Zeghal, N. (2013). Toxic effects of chromium (VI) by maternal ingestion on liver function of female rats and their suckling pups. Environ Toxicol 28: 11–20. 10.1002/tox.20692.21374791
Soudani, N; Ibtissem Ben Amara, N; Troudi, A; Bouaziz, H; Boudawara, T; Zeghal, N. (2011a). Oxidative stress induced by chromium (VI) in bone of suckling rats. Toxicol Ind Health 27: 724–734. 10.1177/0748233710395992.21543464
Soudani, N; Sefi, M; Bouaziz, H; Chtourou, Y; Boudawara, T; Zeghal, N. (2011b). Nephrotoxicity induced by chromium (VI) in adult rats and their progeny. Hum Exp Toxicol 30: 1233–1245. 10.1177/0960327110387454.21056946
Speer, RM; Toyoda, JH; Croom-Perez, TJ; Liu, KJ; Wise, JP. (2021). Particulate hexavalent chromium inhibits E2F1 leading to reduced RAD51 nuclear foci formation in human lung cells. Toxicol Sci 181: 35–46. 10.1093/toxsci/kfab019.33677506
Spiteri, NJ. (1982). Circadian patterning of feeding, drinking and activity during diurnal food access in rats. Physiol Behav 28: 139–147. 10.1016/0031-9384(82)90115-9.7200613
Squier, CA; Kremer, MJ. (2001). Biology of oral mucosa and esophagus [Review]. J Natl Cancer Inst Monogr 29: 7–15.
Standeven, AM; Wetterhahn, KE. (1989). Chromium-vi toxicity uptake reduction and dna damage. J Am Coll Toxicol 8: 1275–1284. 10.3109/10915818909009118.
Standeven, AM; Wetterhahn, KE. (1991). Ascorbate is the principal reductant of chromium (VI) in rat liver and kidney ultrafiltrates. Carcinogenesis 12: 1733–1737. 10.1093/carcin/12.9.1733.1893533
Standeven, AM; Wetterhahn, KE. (1992). Ascorbate is the principal reductant of chromium(VI) in rat lung ultrafiltrates and cytosols, and mediates chromium-DNA binding in vitro. Carcinogenesis 13: 1319–1324. 10.1093/carcin/13.8.1319.1499083
Stanley, JA; Lee, J; Nithy, TK; Arosh, JA; Burghardt, RC; Banu, SK. (2011). Chromium-VI arrests cell cycle and decreases granulosa cell proliferation by down-regulating cyclin-dependent kinases (CDK) and cyclins and up-regulating CDK-inhibitors. Reprod Toxicol 32: 112–123. 10.1016/j.reprotox.2011.05.007.21621607
Stanley, JA; Sivakumar, KK; Arosh, JA; Burghardt, RC; Banu, SK. (2014). Edaravone mitigates hexavalent chromium-induced oxidative stress and depletion of antioxidant enzymes while estrogen restores antioxidant enzymes in the rat ovary in F1 offspring. Biol Reprod 91: 12. 10.1095/biolreprod.113.113332.24804965
Stanley, JA; Sivakumar, KK; Nithy, TK; Arosh, JA; Hoyer, PB; Burghardt, RC; Banu, SK. (2013). Postnatal exposure to chromium through mother's milk accelerates follicular atresia in F1 offspring through increased oxidative stress and depletion of antioxidant enzymes. Free Radic Biol Med 61: 179–196. 10.1016/j.freeradbiomed.2013.02.006.23470461
Stearns, DM. (2000). Is chromium a trace essential metal? [Review]. BioFactors 11: 149–162. 10.1002/biof.5520110301.10875302
Stearns, DM; Kennedy, LJ; Courtney, KD; Giangrande, PH; Phieffer, LS; Wetterhahn, KE. (1995). Reduction of chromium(VI) by ascorbate leads to chromium-DNA binding and DNA strand breaks in vitro. Biochemistry 34: 910–919. 10.1021/bi00003a025.7827049
Stearns, DM; Wetterhahn, KE. (1994). Reaction of chromium(VI) with ascorbate produces chromium(V), chromium(IV), and carbon-based radicals. Chem Res Toxicol 7: 219–230. 10.1021/tx00038a016.8199312
Stearns, DM; Wetterhahn, KE. (1997). Intermediates Produced in the Reaction of Chromium(VI) with Dehydroascorbate Cause Single-Strand Breaks in Plasmid DNA. Chem Res Toxicol 10: 271–278. 10.1021/tx9601521.9084906
Steinhoff, D; ShC, G; Hatfield, GK; Mohr, U. (1986). Carcinogenicity study with sodium dichromate in rats. Exp Toxicol Pathol 30: 129–141. 10.1016/S0232-1513(86)80085-8.
Stella, M; Montaldi, A; Rossi, R; Rossi, G; Levis, AG. (1982). Clastogenic effects of chromium on human lymphocytes in vitro and in vivo. Mutat Res Genet Toxicol 101: 151–164. 10.1016/0165-1218(82)90005-2.
Stern, AH; Yu, CH; Black, K; Lin, L; Lioy, PJ; Gochfeld, M; Fan, ZH. (2010). Hexavalent chromium in house dust--a comparison between an area with historic contamination from chromate production and background locations. Sci Total Environ 408: 4993–4998. 10.1016/j.scitotenv.2010.07.035.20692023
Sterne, JAC; Smith, GD; Cox, DR. (2001). Sifting the evidence -- whaťs wrong with significance tests? Br Med J 322: 226–231.11159626
Stift, A; Friedl, J; Laengle, F. (1998). Liver transplantation for potassium dichromate poisoning [Letter]. N Engl J Med 338: 766–767. 10.1056/NEJM199803123381115.
Stift, A; Friedl, J; Längle, F; Berlakovich, G; Steininger, R; Mühlbacher, F. (2000). Successful treatment of a patient suffering from severe acute potassium dichromate poisoning with liver transplantation. Transplantation 69: 2454–2455.10868660
Stout, MD; Nyska, A; Collins, BJ; Witt, KL; Kissling, GE; Malarkey, DE; Hooth, MJ. (2009). Chronic toxicity and carcinogenicity studies of chromium picolinate monohydrate administered in feed to F344/N rats and B6C3F1 mice for 2 years. Food Chem Toxicol 47: 729–733. 10.1016/j.fct.2009.01.006.19166900
Subramanian, S; Rajendiran, G; Sekhar, P; Gowri, C; Govindarajulu, P; Aruldhas, MM. (2006). Reproductive toxicity of chromium in adult bonnet monkeys (Macaca radiata Geoffrey). Reversible oxidative stress in the semen. Toxicol Appl Pharmacol 215: 237–249. 10.1016/j.taap.2006.03.004.16678873
Sudha, S; Kripa, SK; Shibily, P; Joseph, S; Balachandar, V. (2011). Biomonitoring of genotoxic effects among shielded manual metal arc welders. Asian Pac J Cancer Prev 12: 1041–1044.21790248
Sugden, KD; Campo, CK; Martin, BD. (2001). Direct oxidation of guanine and 7,8-dihydro-8-oxoguanine in DNA by a high-valent chromium complex: a possible mechanism for chromate genotoxicity. Chem Res Toxicol 14: 1315–1322.11559048
Sugden, KD; Stearns, DM. (2000). The role of chromium(V) in the mechanism of chromate-induced oxidative DNA damage and cancer [Review]. J Environ Pathol Toxicol Oncol 19: 215–230.10983888
Sugden, KD; Wetterhahn, KE. (1997). Direct and hydrogen peroxide-induced chromium(V) oxidation of deoxyribose in single-stranded and double-stranded calf thymus DNA. Chem Res Toxicol 10: 1397–1406. 10.1021/tx970135r.9437531
Sugiyama, M; Tsuzuki, K; Ogura, R. (1991). Effect of ascorbic acid on DNA damage, cytotoxicity, glutathione reductase, and formation of paramagnetic chromium in Chinese hamster V-79 cells treated with sodium chromate(VI). J Biol Chem 266: 3383–3386.1847372
Suh, M; Thompson, CM; Kirman, CR; Carakostas, MC; Haws, LC; Harris, MA; Proctor, DM. (2014). High concentrations of hexavalent chromium in drinking water alter iron homeostasis in F344 rats and B6C3F1 mice. Food Chem Toxicol 65: 381–388. 10.1016/j.fct.2014.01.009.24418189
Suh, M; Wikoff, D; Lipworth, L; Goodman, M; Fitch, S; Mittal, L; Ring, C; Proctor, D. (2019). Hexavalent chromium and stomach cancer: a systematic review and meta-analysis. Crit Rev Toxicol 49: 140–159. 10.1080/10408444.2019.1578730.30896278
Sun, H; Zhou, X; Chen, HB; Li, Q; Costa, M. (2009). Modulation of histone methylation and MLH1 gene silencing by hexavalent chromium. Toxicol Appl Pharmacol 237: 258–266. 10.1016/j.taap.2009.04.008.19376149
Suzuki, Y. (1988). Reduction of hexavalent chromium by ascorbic acid in rat lung lavage fluid. Arch Toxicol 62: 116–122. 10.1007/BF00570129.3196146
Suzuki, Y. (1990). Synergism of ascorbic acid and glutathione in the reduction of hexavalent chromium in vitro. Ind Health 28: 9–19.2323964
Suzuki, Y; Fukuda, K. (1990). Reduction of hexavalent chromium by ascorbic acid and glutathione with special reference to the rat lung. Arch Toxicol 64: 169–176. 10.1007/BF02010721.2372230
Taioli, E; Zhitkovich, A; Kinney, P; Udasin, I; Toniolo, P; Costa, M. (1995). Increased DNA-protein crosslinks in lymphocytes of residents living in chromium-contaminated areas. Biol Trace Elem Res 50: 175–180. 10.1007/BF02785408.8962789
Takahashi, Y; Kondo, K; Hirose, T; Nakagawa, H; Tsuyuguchi, M; Hashimoto, M; Sano, T; Ochiai, A; Monden, Y. (2005). Microsatellite instability and protein expression of the DNA mismatch repair gene, hMLH1, of lung cancer in chromate-exposed workers. Mol Carcinog 42: 150–158. 10.1002/mc.20073.15605365
Talattof, A; Amidon, GL. (2018). Pulse packet stochastic model for gastric emptying in the fasted state: A physiological approach. Mol Pharm 15: 2107–2115. 10.1021/acs.molpharmaceut.7b01077.29504768
Tanigawa, T; Araki, S; Sata, F; Nakata, A; Araki, T. (1998). Effects of smoking, aromatic amines, and chromates on CD4+ and CD8+ T lymphocytes in male workers [Comment]. Environ Res 78: 59–63. 10.1006/enrs.1997.3827.9630446
Taniguchi, K; Karin, M. (2018). NF-κB, inflammation, immunity and cancer: coming of age. Nat Rev Immunol 309–324. 10.1038/nri.2017.142.29379212
Tarrant, JM. (2010). Blood cytokines as biomarkers of in vivo toxicity in preclinical safety assessment: Considerations for their use [Review]. Toxicol Sci 117: 4–16. 10.1093/toxsci/kfq134.20447938
TCEQ (Texas Commission on Environmental Quality). (2014). Development support document for hexavalent chromium (particulate compounds). Austin, TX.
Than, BL; Linnekamp, JF; Starr, TK; Largaespada, DA; Rod, A; Zhang, Y; Bruner, V; Abrahante, J; Schumann, A; Luczak, T; Walter; Niemczyk, A; O'Sullivan, MG; Medema, JP; Fijneman, RJ; Meijer, GA; Van Den Broek, E; Hodges, CA; Scott, PM; Vermeulen, L; Cormier, RT. (2016). CFTR is a tumor suppressor gene in murine and human intestinal cancer. Oncogene 35: 4179–4187. 10.1038/onc.2015.483.
Thermo Fisher (Thermo Fisher Scientific Inc.). (2009). Safety data sheet: Potassium dichromate.
Thomann, RV; Snyder, CA; Squibb, KS. (1994). Development of a pharmacokinetic model for chromium in the rat following subchronic exposure: I. The importance of incorporating long-term storage compartment. Toxicol Appl Pharmacol 128: 189–198. 10.1006/taap.1994.1197.7940533
Thompson, CM; Donahue, DA; Hobbs, C; Costecalde, Y; Franzen, A; Suh, M; Proctor, DM; Harris, MA. (2020). Exposure to environmentally-relevant concentrations of hexavalent chromium does not induce ovarian toxicity in mice. Regul Toxicol Pharmacol 116: 104729. 10.1016/j.yrtph.2020.104729.32652207
Thompson, CM; Fedorov, Y; Brown, DD; Suh, M; Proctor, DM; Kuriakose, L; Haws, LC; Harris, MA. (2012a). Assessment of Cr(VI)-induced cytotoxicity and genotoxicity using high content analysis. PLoS ONE 7: e42720. 10.1371/journal.pone.0042720.22905163
Thompson, CM; Kirman, CR; Proctor, DM; Haws, LC; Suh, M; Hays, SM; Hixon, JG; Harris, MA. (2014). A chronic oral reference dose for hexavalent chromium-induced intestinal cancer. J Appl Toxicol 34: 525–536. 10.1002/jat.2907.23943231
Thompson, CM; Proctor, DM; Haws, LC; Hébert, CD; Grimes, SD; Shertzer, HG; Kopec, AK; Hixon, JG; Zacharewski, TR; Harris, MA. (2011). Investigation of the mode of action underlying the tumorigenic response induced in B6C3F1 mice exposed orally to hexavalent chromium. Toxicol Sci 123: 58–70. 10.1093/toxsci/kfr164.21712504
Thompson, CM; Proctor, DM; Suh, M; Haws, LC; Hébert, CD; Mann, JF; Shertzer, HG; Hixon, JG; Harris, MA. (2012b). Comparison of the effects of hexavalent chromium in the alimentary canal of F344 rats and B6C3F1 mice following exposure in drinking water: implications for carcinogenic modes of action. Toxicol Sci 125: 79–90. 10.1093/toxsci/kfr280.22011396
Thompson, CM; Proctor, DM; Suh, M; Haws, LC; Kirman, CR; Harris, MA. (2013). Assessment of the mode of action underlying development of rodent small intestinal tumors following oral exposure to hexavalent chromium and relevance to humans [Review]. Crit Rev Toxicol 43: 244–274. 10.3109/10408444.2013.768596.23445218
Thompson, CM; Seiter, J; Chappell, MA; Tappero, RV; Proctor, DM; Suh, M; Wolf, JC; Haws, LC; Vitale, R; Mittal, L; Kirman, CR; Hays, SM; Harris, MA. (2015a). Synchrotron-based imaging of chromium and γ-H2AX immunostaining in the duodenum following repeated exposure to Cr(VI) in drinking water. Toxicol Sci 143: 16–25. 10.1093/toxsci/kfu206.25352572
Thompson, CM; Wolf, JC; Elbekai, RH; Paranjpe, MG; Seiter, JM; Chappell, MA; Tappero, RV; Suh, M; Proctor, DM; Bichteler, A; Haws, LC; Harris, MA. (2015b). Duodenal crypt health following exposure to Cr(VI): Micronucleus scoring, γ-H2AX immunostaining, and synchrotron X-ray fluorescence microscopy. Mutat Res Genet Toxicol Environ Mutagen 789-790: 61–66. 10.1016/j.mrgentox.2015.05.004.
Thompson, CM; Young, RR; Dinesdurage, H; Suh, M; Harris, MA; Rohr, AC; Proctor, DM. (2017). Assessment of the mutagenic potential of hexavalent chromium in the duodenum of big blue® rats. Toxicol Appl Pharmacol 330: 48–52. 10.1016/j.taap.2017.07.002.28687238
Thompson, CM; Young, RR; Suh, M; Dinesdurage, HR; Elbekai, RH; Harris, MA; Rohr, AC; Proctor, DM. (2015c). Assessment of the mutagenic potential of Cr(VI) in the oral mucosa of Big Blue((R)) transgenic F344 rats. Environ Mol Mutagen 56: 621–628. 10.1002/em.21952.26010270
Tian, M; Guo, F; Sun, Y; Zhang, W; Miao, F; Liu, Y; Song, G; Ho, CL; Yu, X; Sun, JZ; Wong, WY. (2014). A fluorescent probe for intracellular cysteine overcoming the interference by glutathione. Org Biomol Chem 12: 6128–6133. 10.1039/c4ob00382a.24991968
Tielemans, E; Burdorf, A; Te Velde, ER; Weber, RFA; Van Kooij, RJ; Veulemans, H; Heederik, DJJ. (1999). Occupationally related exposures and reduced semen quality: A case-control study. Fertil Steril 71: 690–696.10202880
Toebak, MJ; Pohlmann, PR; Sampat-Sardjoepersad, SC; von Blomberg, BM; Bruynzeel, DP; Scheper, RJ; Rustemeyer, T; Gibbs, S. (2006). CXCL8 secretion by dendritic cells predicts contact allergens from irritants. Toxicol In Vitro 20: 117–124. 10.1016/j.tiv.2005.06.039.16099135
Tong, Z; Zhang, C. (2003). [Study on liver toxic damage of occupational chromium exposure]. Anquan Jiankang he Huanjing/Safety Health and Environment (3): 21.
Travlos, GS; Mirris, RW; Elwell, MR; Duke, A; Rosenblum, S; Thompson, MB. (1996). Frequency and relationships of clinical chemistry and liver and kidney histopathology findings in 13-week toxicity studies in rats. Toxicology 107: 17–29. 10.1016/0300-483X(95)03197-N.8597028
Trivedi, B; Saxena, DK; Murthy, RC; Chandra, SV. (1989). Embryotoxicity and fetotoxicity of orally administered hexavalent chromium in mice. Reprod Toxicol 3: 275–278. 10.1016/0890-6238(89)90022-1.2520531
Trzeciak, A; Kowalik, J; Małecka-Panas, E; Drzewoski, J; Wojewódzka, M; Iwaneńko, T; Błasiak, J. (2000). Genotoxicity of chromium in human gastric mucosa cells and peripheral blood lymphocytes evaluated by the single cell gel electrophoresis (comet assay). Med Sci Monit 6: 24–29.11208279
Tsao, DA; Tseng, WC; Chang, HR. (2011). The expression of RKIP, RhoGDI, galectin, c-Myc and p53 in gastrointestinal system of Cr(VI)-exposed rats. J Appl Toxicol 31: 730–740. 10.1002/jat.1621.21437922
Tsukamoto, T; Mizoshita, T; Tatematsu, M. (2007). Animal models of stomach carcinogenesis [Review]. Toxicol Pathol 35: 636–648. 10.1080/01926230701420632.17654405
Tully, DB; Collins, BJ; Overstreet, JD; Smith, CS; Dinse, GE; Mumtaz, MM; Chapin, RE. (2000). Effects of arsenic, cadmium, chromium, and lead on gene expression regulated by a battery of 13 different promoters in recombinant HepG2 cells. Toxicol Appl Pharmacol 168: 79–90. 10.1006/taap.2000.9014.11032763
Turk, JL; Parker, D. (1977). Sensitization with Cr, Ni, and Zr salts and allergic type granuloma formation in the guinea pig. J Invest Dermatol 68: 341–345.864275
U.S. EPA (U.S. Environmental Protection Agency). (1986a). Effect of chlorine on chromium speciation in tap water [EPA Report]. (EPA/600/M-86/015). Washington, D.C.: U.S. Enviromental Protection Agency.
U.S. EPA (U.S. Environmental Protection Agency). (1986b). Guidelines for carcinogen risk assessment [EPA Report] (pp. 33993–34003). (EPA/630/R-00/004). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://cfpub.epa.gov/ncea/raf/car2sab/guidelines_1986.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (1986c). Guidelines for mutagenicity risk assessment (pp. 1–17). (ISSN 0097-6326 EISSN 2167-2520 EPA/630/R-98/003). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/guidelines-mutagenicity-risk-assessment.
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855.
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996a). Guidelines for reproductive toxicity risk assessment [EPA Report]. (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30004YQB.txt.
U.S. EPA (U.S. Environmental Protection Agency). (1996b). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1996c). Proposed guidelines for carcinogen risk assessment: notice of availability and opportunity to comment. Fed Reg 61: 17960–18011.
U.S. EPA (U.S. Environmental Protection Agency). (1998a). Guidelines for neurotoxicity risk assessment [EPA Report]. (EPA/630/R-95/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/risk/guidelinesneurotoxicity-risk-assessment.
U.S. EPA (U.S. Environmental Protection Agency). (1998b). Health effects test guidelines OPPTS 870.7800 immunotoxicity. (EPA 712-C-98–351). Washington, DC: Prevention, Pesticides and Toxic Substances, U.S. Environmental Protection Agency. http://www.epa.gov/ocspp/pubs/frs/publications/Test_Guidelines/series870.htm.
U.S. EPA (U.S. Environmental Protection Agency). (1998c). Toxicological review of hexavalent chromium [EPA Report] (pp. 80). (630R98009). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0144tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens [EPA Report]. (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/supplemental-guidance-assessing-susceptibility-early-life-exposure-carcinogens.
U.S. EPA (U.S. Environmental Protection Agency). (2006a). 2006 community water system survey -Volume I: Overview [EPA Report]. (EPA 815-R-09–001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009JJI.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2006b). 2006 community water system survey Volume II: Detailed tables and survey methodology [EPA Report]. (EPA 815-R-09–002). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009USA.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2006c). Approaches for the application of physiologically based pharmacokinetic (PBPK) models and supporting data in risk assessment (Final Report) [EPA Report] (pp. 1–123). (EPA/600/R-05/043F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=157668.
U.S. EPA (U.S. Environmental Protection Agency). (2006d). A framework for assessing health risk of environmental exposures to children. (EPA/600/R-05/093F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=158363.
U.S. EPA (U.S. Environmental Protection Agency). (2008). Reregistration eligibility decision for chromated arsenicals. (EPA 739-R-08–006). Office of Prevention, Pesticides And Toxic Substances; U.S. Environmental Protection Agency.
U.S. EPA (U.S. Environmental Protection Agency). (2009). Risk assessment guidance for superfund volume I: Human health evaluation manual (Part F, supplemental guidance for inhalation risk assessment): Final [EPA Report]. (EPA/540/-R-070/002). Washington, DC. https://www.epa.gov/risk/risk-assessment-guidance-superfund-rags-part-f.
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Exposure factors handbook: 2011 edition [EPA Report]. (EPA/600/R-090/052F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100F2OS.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2011b). (Fourth) Five-year review report for United Chrome Products ORD 009043001 Corvallis, Benton County, Oregon Draft August 2011 revision 5. Seattle, WA: U.S. Environmental Protection Agency Region 10.
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011d). Toxicological review of trichloroethylene (CAS No. 79–01-6) in support of summary Information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R09011F). Washington, DC. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100CB6V.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark Dose Software (BMDS): Version 2.2. Retrieved from https://www.epa.gov/bmds
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2012c). The third Unregulated Contaminant Monitoring Rule (UCMR 3). Presentation presented at US EPA Webinar, September, 2012, OGWDW, SRMD Technical Support Center Cincinnati Ohio.
U.S. EPA (U.S. Environmental Protection Agency). (2012d). Toxicological review of tetrachloroethylene (Perchloroethylene) (CASRN 127–18-4) in support of summary information on the Integrated Risk Information System (IRIS). (EPA/635/R-08/011F). Washington, DC: National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0106tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2013). Toxicological review of Methanol (Noncancer) (CASRN 67–56-1) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-11–001F). Washington, DC. https://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100GZGY.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2014a). Discharge monitoring report (DMR) pollutant loading tool. Washington, DC. Retrieved from https://cfpub.epa.gov/dmr/index.cfm
U.S. EPA (U.S. Environmental Protection Agency). (2014b). Preliminary materials for the Integrated Risk Information System (IRIS) toxicological review of hexavalent chromium part 1: Experimental animal studies [CASRN) 18540–29-9] [EPA Report]. (EPA/635/R-14/094). Research Triangle Park, NC. https://www.epa.gov/iris/iris-bimonthly-public-meeting-jun-2014.
U.S. EPA (U.S. Environmental Protection Agency). (2014c). Preliminary materials for the Integrated Risk Information System (IRIS) toxicological review of hexavalent chromium part 2: Human, toxicokinetic, and mechanistic Studies [CASRN) 18540–29-9] [EPA Report]. (EPA/635/R-14/218). Research Triangle Park, NC. https://www.epa.gov/iris/iris-bimonthly-public-meeting-oct-2014.
U.S. EPA (U.S. Environmental Protection Agency). (2014d). The third Unregulated Contaminant Monitoring Rule (UCMR 3) occurrence data. Retrieved from http://water.epa.gov/lawsregs/rulesregs/sdwa/ucmr/data.cfm#ucmr2013
U.S. EPA (U.S. Environmental Protection Agency). (2014e). Toxicological review of libby amphibole asbestos: In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-11/002F). Washington, DC: Integrated Risk Information System, National Center for Environmental Assessment, Office of Research and Development. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1026tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). 2014 National Emissions Inventory (NEI) data (Version 2). Washington, DC. Retrieved from https://www.epa.gov/air-emissions-inventories/2014-national-emissions-inventory-nei-data
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Evaluation of the inhalation carcinogenicity of ethylene oxide (CASRN 75–21-8): In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R16350Fa). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1025tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016c). US EPA’s report on the environment (ROE). Available online at https://cfpub.epa.gov/roe/index.cfm (accessed
U.S. EPA (U.S. Environmental Protection Agency). (2018). Toxic Release Inventory (TRI). Retrieved from https://www.epa.gov/enviro/tri-search
U.S. EPA (U.S. Environmental Protection Agency). (2019). Systematic Review Protocol for the Hexavalent Chromium IRIS Assessment (Preliminary Assessment Materials) [EPA Report]. (EPA/635/R-18/155).
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Benchmark Dose Software (BMDS). Version 3.2: User guide [EPA Report]. (EPA/600/R-20/216). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10103T2.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2020b). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA600R20137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Model log files for the IRIS toxicological review of hexavalent chromium.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). National Emissions Inventory (NEI). Available online at https://www.epa.gov/air-emissions-inventories/national-emissions-inventory-nei (accessed February 10, 2021).
U.S. EPA (U.S. Environmental Protection Agency). (2021c). TRI Toxics Tracker. Available online at https://edap.epa.gov/public/extensions/TRIToxicsTracker/TRIToxicsTracker.html (accessed
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
Uddin, AN; Burns, FJ; Rossman, TG; Chen, H; Kluz, T; Costa, M. (2007). Dietary chromium and nickel enhance UV-carcinogenesis in skin of hairless mice. Toxicol Appl Pharmacol 221: 329–338. 10.1016/j.taap.2007.03.030.17499830
Urbano, AM; Ferreira, LMR; Alpoim, MC. (2012). Molecular and cellular mechanisms of hexavalent chromium-induced lung cancer: An updated perspective [Review]. Curr Drug Metab 13: 284–305.22455553
USGS (U.S. Geological Survey). (1995). Chromium life cycle study. (IC 9411). Washington, D.C.: U.S. Department of the Interior, Bureau of Mines.
Vaglenov, A; Nosko, M; Georgieva, R; Carbonell, E; Creus, A; Marcos, R. (1999). Genotoxicity and radioresistance in electroplating workers exposed to chromium. Mutat Res 446: 23–34.10613183
Valentine, CC; Young, RR; Fielden, MR; Kulkarni, R; Williams, LN; Li, T; Minocherhomji, S; Salk, JJ. (2020). Direct quantification of in vivo mutagenesis and carcinogenesis using duplex sequencing. Proc Natl Acad Sci USA 117: 33414–33425. 10.1073/pnas.2013724117.33318186
van Heerden, PV; Jenkins, IR; Woods, WP; Rossi, E; Cameron, PD. (1994). Death by tanning--a case of fatal basic chromium sulphate poisoning [Review]. Intensive Care Med 20: 145–147.8201096
van Oud Alblas, AB; van Furth, R. (1979). Origin, Kinetics, and characteristics of pulmonary macrophages in the normal steady state. J Exp Med 149: 1504–1518.448291
Vandamme, D; Herrero, A; Al-Mulla, F; Kolch, W. (2014). Regulation of the MAPK pathway by Raf kinase inhibitory protein [Review]. Crit Rev Oncog 19: 405–415. 10.1615/critrevoncog.2014011922.25597351
Vanhauwaert, A; Vanparys, P; Kirsch-Volders, M. (2001). The in vivo gut micronucleus test detects clastogens and aneugens given by gavage. Mutagenesis 16: 39–50. 10.1093/mutage/16.1.39.11139597
Vengosh, A; Coyte, R; Karr, J; Harkness, JS; Kondash, AJ; Ruhl, LS; Merola, RB; Dywer, GS. (2016). Origin of hexavalent chromium in drinking water wells from the piedmont aquifers of North Carolina. Environ Sci Technol Lett 3: 409–414. 10.1021/acs.estlett.6b00342.
Verschoor, MA; Bragt, PC; Herber, RFM; Zielhuis, RL; Zwennis, WCM. (1988). Renal function of chrome-plating workers and welders. Int Arch Occup Environ Health 60: 67–70. 10.1007/BF00409381.3350606
Videla, LA; Rodrigo, R; Orellana, M; Fernandez, V; Tapia, G; Quiñones, L; Varela, N; Contreras, J; Lazarte, R; Csendes, A; Rojas, J; Maluenda, F; Burdiles, P; Diaz, JC; Smok, G; Thielemann, L; Poniachik, J. (2004). Oxidative stress-related parameters in the liver of non-alcoholic fatty liver disease patients. Clin Sci (Lond) 106: 261–268. 10.1042/CS20030285.14556645
Viechtbauer, W. (2010). Conducting meta-analyses in R with the metafor package. J Stat Softw 36: 1–48.
Viegas, S; Martins, C; Bocca, B; Bousoumah, R; Duca, RC; Galea, KS; Godderis, L; Iavicoli, I; Janasik, B; Jones, K; Leese, E; Leso, V; Ndaw, S; van Nieuwenhuyse, A; Poels, K; Porras, SP; Ruggieri, F; Silva, MJ; Verdonck, J; Wasowicz, W; Scheepers, PTJ; Santonen, T; Hbm Eu Chromates Study Team, T. (2022). HBM4EU Chromates Study: Determinants of Exposure to Hexavalent Chromium in Plating, Welding and Other Occupational Settings. Int J Environ Res Public Health 19. 10.3390/ijerph19063683.
Vigliani, EC; Zurlo, N. (1955). Erfahrungen der Clinica del Lavoro mit einigen maximalen Arbeitsplatzkonzentrationen (MAK) von Industriegiften. Int Arch Occup Environ Health 13: 528–534. 10.1007/BF00312756.
Vincent, J. (2013). Chromium: is it essential, pharmacologically relevant, or toxic? In Interrelations between Essential Metal Ions and Human Diseases: Springer. 10.1007/978-94-007-7500-8_6.
Vincent, JB. (2017). New evidence against chromium as an essential trace element. J Nutr 147: 2212–2219. 10.3945/jn.117.255901.29021369
Voitkun, V; Zhitkovich, A; Costa, M. (1998). Cr(III)-mediated crosslinks of glutathione or amino acids to the DNA phosphate backbone are mutagenic in human cells. Nucleic Acids Res 26: 2024–2030.9518499
Vosoughifar, M. (2016). Preparation and application of copper ferrite nanoparticles for degradation of methyl orange. Journal of Materials Science: Materials in Electronics 27: 10449–10453. 10.1007/s10854-016-5133-x.
Vreeburg, KJ; de Groot, K; van Hoogstraten, IM; von Blomberg, BM; Scheper, RJ. (1991). Successful induction of allergic contact dermatitis to mercury and chromium in mice. International Arch Allergy Appl Immunol 96: 179–183. 10.1159/000235491.
Wakeman, TP; Yang, A; Dalal, NS; Boohaker, RJ; Zeng, Q; Ding, Q; Xu, B. (2017). DNA mismatch repair protein Mlh1 is required for tetravalent chromium intermediate-induced DNA damage. Onct 8: 83975–83985. 10.18632/oncotarget.20150.
Wang, BJ; Guo, YL; Chang, HY; Sheu, HM; Pan, MH; Lee, YH; Wang, YJ. (2010a). N-acetylcysteine inhibits chromium hypersensitivity in coadjuvant chromium-sensitized albino guinea pigs by suppressing the effects of reactive oxygen species. Exp Dermatol 19: e191–e200. 10.1111/j.1600-0625.2009.01045.x.20113346
Wang, BJ; Sheu, HM; Guo, YL; Lee, YH; Lai, CS; Pan, MH; Wang, YJ. (2010b). Hexavalent chromium induced ROS formation, Akt, NF-kappaB, and MAPK activation, and TNF-alpha and IL-1alpha production in keratinocytes. Toxicol Lett 198: 216–224. 10.1016/j.toxlet.2010.06.024.20619327
Wang, L; Qiu, JG; He, J; Liu, WJ; Ge, X; Zhou, FM; Huang, YX; Jiang, BH; Liu, LZ. (2019). Suppression of miR-143 contributes to overexpression of IL-6, HIF-1α and NF-κB p65 in Cr(VI)-induced human exposure and tumor growth. Toxicol Appl Pharmacol 378: 114603. 10.1016/j.taap.2019.114603.31152816
Wang, TC; Jia, G; Song, Y, anS; Zhang, J, i; Ma, Y, anHui; Feng, W, eiYue; Leu, L, anZ; Zhang, N; Zhou, JW, en; Yan, L, ei; Zhen, S, en; Qian, Q, in. (2012a). Effects of chronic chromate exposure on human serum prostate specific antigen: A cross sectional study. Ind Health 50: 95–102. 10.2486/indhealth.MS1278.22293723
Wang, TC; Song, YS; Wang, H; Zhang, J; Yu, SF; Gu, YE; Chen, T; Wang, Y; Shen, HQ; Jia, G. (2012b). Oxidative DNA damage and global DNA hypomethylation are related to folate deficiency in chromate manufacturing workers. J Hazard Mater 213–214: 440–446. 10.1016/j.jhazmat.2012.02.024.
Wang, X; Qin, Q; Xu, X; Xu, J; Wang, J; Zhou, J; Huang, S; Zhai, W; Zhou, H; Chen, J. (1994). Chromium-Induced Early Changes in Renal Function among Ferrochromium-Producing Workers. Toxicology 90: 93–101. 10.1016/0300-483X(94)90208-9.7912862
Wang, XF; Lou, XM; Shen, Y; Xing, ML; Xu, LH. (2010c). Apoptotic-related protein changes induced by hexavalent chromium in mice liver. Environ Toxicol 25: 77–82. 10.1002/tox.20478.19219935
Wang, XF; Xing, ML; Shen, Y; Zhu, X; Xu, LH. (2006). Oral administration of Cr(VI) induced oxidative stress, DNA damage and apoptotic cell death in mice. Toxicology 228: 16–23. 10.1016/j.tox.2006.08.005.16979809
Wang, Y; Wu, W; Yao, C; Lou, J; Chen, R; Jin, L; Wu, N; Gao, M; Song, P; Tan, Y; Liu, K. (2015). Elevated tissue Cr levels, increased plasma oxidative markers, and global hypomethylation of blood DNA in male Sprague-Dawley rats exposed to potassium dichromate in drinking water. Environ Toxicol. 10.1002/tox.22117.
Wang, Z; Peng, H; Zhang, R; Jiang, X; Chen, S; Guo, P; Xiao, Y; Zeng, X; Wang, Q; Aschner, M; Chou, WC; Li, D; Chen, W; Chen, L. (2022). Assessment of intestinal injury of hexavalent chromium using a modified in vitro gastrointestinal digestion model. Toxicol Appl Pharmacol 436: 115880. 10.1016/j.taap.2022.115880.35016909
Wang, Z; Yang, C. (2019). Metal carcinogen exposure induces cancer stem cell-like property through epigenetic reprograming: A novel mechanism of metal carcinogenesis [Review]. Semin Cancer Biol 57: 95–104. 10.1016/j.semcancer.2019.01.002.30641125
Ward, FW; Coates, ME. (1987). Gastrointestinal pH measurement in rats: Influence of the microbial flora, diet and fasting. Lab Anim 21: 216–222. 10.1258/002367787781268693.3626468
Waters, AM; Der, CJ. (2018). KRAS: The critical driver and therapeutic target for pancreatic cancer [Review]. Cold Spring Harb Perspect Med 8: a031435. 10.1101/cshperspect.a031435.29229669
Wear, HM; Mcpike, MJ; Watanabe, KH. (2016). From primordial germ cells to primordial follicles: A review and visual representation of early ovarian development in mice [Review]. Journal of Ovarian Research 9: 36. 10.1186/s13048-016-0246-7.27329176
Welling, R; Beaumont, JJ; Petersen, SJ; Alexeeff, GV; Steinmaus, C. (2015). Chromium VI and stomach cancer: a meta-analysis of the current epidemiological evidence [Review]. Occup Environ Med 72: 151–159. 10.1136/oemed-2014-102178.25231674
Werfel, U; Langen, V; Eickhoff, I; Schoonbrood, J; Vahrenholz, C; Brauksiepe, A; Popp, W; Norpoth, K. (1998). Elevated DNA single-strand breakage frequencies in lymphocytes of welders exposed to chromium and nickel. Carcinogenesis 19: 413–418.9525274
Westbrook, A, yaM; Szakmary, A; Schiestl, RH. (2010). Mechanisms of intestinal inflammation and development of associated cancers: Lessons learned from mouse models [Review]. Mutat Res Rev Mutat Res 705: 40–59. 10.1016/j.mrrev.2010.03.001.
Wetterhahn, KE; Hamilton, JW; Aiyar, J; Borges, KM; Floyd, R. (1989). Mechanism of chromium(VI) carcinogenesis: Reactive intermediates and effect on gene expression [Review]. Biol Trace Elem Res 21: 405–411. 10.1007/BF02917282.2484620
Whalan, JE. (2000). A guide to clinical pathology in animals. Whalan, JE.
Whalan, JE. (2015). Clinical Chemistry. 67–94. 10.1007/978-3-319-15853-2_6.
WHO (World Health Organization). (2003). Chromium in drinking water. (WHO/SDE/WSH/03.04/04). Geneva, Switzerland. http://www.who.int/water_sanitation_health/dwq/chemicals/chromium.pdf.
WHO (World Health Organization). (2010). WHO laboratory manual for the examination and processing of human semen. In WHO laboratory manual for the examination and processing of human semen (5th ed.). Geneva, Switzerland.
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1985). Fast uptake kinetics in vitro of 51Cr (VI) by red blood cells of man and rat. Arch Toxicol 57: 31–34. 10.1007/BF00286571.4015396
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1986). Disposition of a soluble chromate in the isolated perfused rat liver. Xenobiotica 16: 839–844. 10.3109/00498258609038965.3765662
Williams, AB; Schumacher, B. (2016). p53 in the DNA-Damage-Repair Process [Review]. Cold Spring Harb Perspect Med 6. 10.1101/cshperspect.a026070.
Wisconsin DHS (Wisconsin Department of Health Services). (2010). Chromium. Available online at http://www.dhs.wisconsin.gov/eh/ChemFS/fs/chromium.htm (accessed
Wise, JP; Young, JL; Cai, J; Cai, L. (2022). Current understanding of hexavalent chromium [Cr(VI)] neurotoxicity and new perspectives [Review]. Environ Int 158: 106877. 10.1016/j.envint.2021.106877.34547640
Wise, SS; Aboueissa, AE; Martino, J; Wise, JP. (2018). Hexavalent chromium-induced chromosome instability drives permanent and heritable numerical and structural changes and a dna repair-deficient phenotype. Cancer Res 78: 4203–4214. 10.1158/0008-5472.CAN-18-0531.29880483
Wise, SS; Holmes, AL; Liou, L; Adam, RM; Wise, JP. (2016). Hexavalent chromium induces chromosome instability in human urothelial cells. Toxicol Appl Pharmacol 296: 54–60. 10.1016/j.taap.2016.02.015.26908176
Wise, SS; Wise, JP, Sr. (2010). Aneuploidy as an early mechanistic event in metal carcinogenesis [Review]. Biochem Soc Trans 38: 1650–1654. 10.1042/BST0381650.21118142
Witt, KL; Stout, MD; Herbert, RA; Travlos, GS; Kissling, GE; Collins, BJ; Hooth, MJ. (2013). Mechanistic Insights from the NTP Studies of Chromium. Toxicol Pathol 41: 326–342. 10.1177/0192623312469856.23334696
Wong, V; Armknecht, S; Zhitkovich, A. (2012). Metabolism of Cr(VI) by ascorbate but not glutathione is a low oxidant-generating process. 26: 192–196. 10.1016/j.jtemb.2012.04.016.22572042
Wu, FY; Tsai, FJ; Kuo, HW; Tsai, CH; Wu, WY; Wang, RY; Lai, JS. (2000). Cytogenetic study of workers exposed to chromium compounds. Mutat Res Genet Toxicol Environ Mutagen 464: 289–296. 10.1016/S1383-5718(99)00206-5.
Wu, FY; Wu, WY; Kuo, HW; Liu, CS; Wang, RY; Lai, JS. (2001). Effect of genotoxic exposure to chromium among electroplating workers in Taiwan. Sci Total Environ 279: 21–28.11712598
Wultsch, G; Nersesyan, A; Kundi, M; Jakse, R; Beham, A; Wagner, KH; Knasmueller, S. (2014). The sensitivity of biomarkers for genotoxicity and acute cytotoxicity in nasal and buccal cells of welders. Int J Hyg Environ Health 217: 492–498. 10.1016/j.ijheh.2013.09.005.24698449
Wultsch, G; Nersesyan, A; Kundi, M; Mišík, M; Setayesh, T; Waldherr, M; Vodicka, P; Vodickova, L; Knasmüller, S. (2017). Genotoxic and cytotoxic effects in exfoliated buccal and nasal cells of chromium and cobalt exposed electroplaters. J Toxicol Environ Health A 80: 1–10. 10.1080/15287394.2017.1286918.27898270
Xia, B; Yuan, J; Pang, L; He, K. (2022). Chromium [Cr(VI)] exposure causes cytotoxicity of human bronchial epithelial cells (16-HBE) and proteomic alterations. Int J Toxicol 41: 10915818221078277. 10.1177/10915818221078277.
Xia, W; Hu, J; Zhang, B; Li, Y; Wise, JP; Bassig, BA; Zhou, A; Savitz, DA; Xiong, C; Zhao, J; Du, X; Zhou, Y; Pan, X; Yang, J; Wu, C; Jiang, M; Peng, Y; Qian, Z; Zheng, T; Xu, S. (2016). A case-control study of maternal exposure to chromium and infant low birth weight in China. Chemosphere 144: 1484–1489. 10.1016/j.chemosphere.2015.10.006.26498095
Xiao, F; Feng, X; Zeng, M; Guan, L; Hu, Q; Zhong, C. (2012a). Hexavalent chromium induces energy metabolism disturbance and p53-dependent cell cycle arrest via reactive oxygen species in L-02 hepatocytes. Mol Cell Biochem 371: 65–76. 10.1007/s11010-012-1423-7.22886373
Xiao, F; Li, Y; Dai, L; Deng, Y; Zou, Y; Li, P; Yang, Y; Zhong, C. (2012b). Hexavalent chromium targets mitochondrial respiratory chain complex I to induce reactive oxygen species-dependent caspase-3 activation in L-02 hepatocytes. Int J Mol Med 30: 629–635. 10.3892/ijmm.2012.1031.22710416
Xiao, F; Li, Y; Luo, L; Xie, Y; Zeng, M; Wang, A; Chen, H; Zhong, C. (2014). Role of mitochondrial electron transport chain dysfunction in Cr(VI)-induced cytotoxicity in L-02 hepatocytes. Cell Physiol Biochem 33: 1013–1025. 10.1159/000358672.24732427
Xiao, Y; Zeng, M; Yin, L; Li, N; Xiao, F. (2019). Clusterin increases mitochondrial respiratory chain complex I activity and protects against hexavalent chromium-induced cytotoxicity in L-02 hepatocytes. Toxicology Research 8: 15–24. 10.1039/c8tx00231b.30713657
Xiaohua, L; Yanshuang, S; Li, W; Yuhui, L; Ji, Z; Yanhui, M; Yun, W; Wenjun, M; Lei, Y; Guang, J. (2012). Evaluation of the correlation between genetic damage and occupational chromate exposure through BNMN frequencies. J Occup Environ Med 54: 166–170. 10.1097/JOM.0b013e31823d86b4.22157804
Xie, Y; Xiao, F; Luo, L; Zhong, C. (2014). Activation of autophagy protects against ROS-mediated mitochondria-dependent apoptosis in L-02 hepatocytes induced by Cr(VI). Cell Physiol Biochem 33: 705–716. 10.1159/000358646.24643125
Xu, J; Zhao, M; Pei, L; Zhang, R; Liu, X; Wei, L; Yang, M; Xu, Q. (2018). Oxidative stress and DNA damage in a long-term hexavalent chromium-exposed population in North China: a cross-sectional study. BMJ Open 8: e021470. 10.1136/bmjopen-2017-021470.
Yamate, J; Izawa, T; Kuwamura, M. (2016). Histopathological analysis of rat hepatotoxicity based on macrophage functions: In particular, an analysis for thioacetamide-induced hepatic lesions [Review]. Food Saf 4: 61–73. 10.14252/foodsafetyfscj.2016012.
Yang, F; Zhao, L; Mei, D; Jiang, L; Geng, C; Li, Q; Yao, X; Liu, Y; Kong, Y; Cao, J. (2017). HMGA2 plays an important role in Cr (VI)-induced autophagy. Int J Cancer 141: 986–997. 10.1002/ijc.30789.28510366
Yang, L. (2006). Incidence and mortality of gastric cancer in China [Review]. World J Gastroenterol 12: 17–20. 10.3748/wjg.v12.i1.17.16440411
Yazar, S; Yildirim, IY. (2018). Oxidative DNA damage in electroplaters co-exposed to chromium and nickel. Fresen Environ Bull 27: 6831–6836.
Yi, X; Xiao, F; Zhong, X; Duan, Y; Liu, K; Zhong, C. (2017). A Ca(2+) chelator ameliorates chromium (VI)-induced hepatocyte L-02 injury via down-regulation of voltage-Dependent anion channel 1 (VDAC1) expression. Environ Toxicol Pharmacol 49: 27–33. 10.1016/j.etap.2016.11.007.27898307
Yi, X; Zhang, Y; Zhong, C; Zhong, X; Xiao, F. (2016). The role of STIM1 in the Cr(vi)-induced [Ca(2+)]i increase and cell injury in L-02 hepatocytes. Metallomics 8: 1273–1282. 10.1039/c6mt00204h.27868128
Yoisungnern, T; Das, J; Choi, YJ; Parnpai, R; Kim, JH. (2015). Effect of hexavalent chromium-treated sperm on in vitro fertilization and embryo development. Toxicol Ind Health. 10.1177/0748233715579805.
Youn, JS; Csavina, J; Rine, KP; Shingler, T; Taylor, MP; Sáez, AE; Betterton, EA; Sorooshian, A. (2016). Hygroscopic properties and respiratory system deposition behavior of particulate matter emitted by mining and smelting operations. Environ Sci Technol 50: 11706–11713. 10.1021/acs.est.6b03621.27700056
Younan, S; Sakita, GZ; Coluna, JGY; Rufino, MN; Keller, R; Bremer-Neto, H. (2019). Probiotic mitigates the toxic effects of potassium dichromate in a preclinical study: A randomized controlled trial. J Sci Food Agric 99: 183–190. 10.1002/jsfa.9159.29851070
Younossi, ZM. (2019). Non-alcoholic fatty liver disease – A global public health perspective [Review]. J Hepatol 70: 531–544. 10.1016/j.jhep.2018.10.033.30414863
Yousef, MI; El-Demerdash, FM; Kamil, KI; Elaswad, FA. (2006). Ameliorating effect of folic acid on chromium(VI)-induced changes in reproductive performance and seminal plasma biochemistry in male rabbits. Reprod Toxicol 21: 322–328. 10.1016/j.reprotox.2005.09.005.16249067
Yu, A; Jackson, T; Tsume, Y; Koenigsknecht, M; Wysocki, J; Marciani, L; Amidon, GL; Frances, A; Baker, JR; Hasler, W; Wen, B; Pai, A; Sun, D. (2017). Mechanistic Fluid Transport Model to Estimate Gastrointestinal Fluid Volume and Its Dynamic Change Over Time. AAPS J 19: 1682–1690. 10.1208/s12248-017-0145-x.28980204
Yuan, JH. (1993). Modeling blood/plasma concentrations in dosed feed and dosed drinking water toxicology studies. Toxicol Appl Pharmacol 119: 131–141.8470117
Yuan, WM; Lu, YQ; Wei, Z; Chen, M; He, SL; Mai, WY; Zhang, MB. (2016). An epistaxis emergency associated with multiple pollutants in elementary students. Biomed Environ Sci 29: 893–897. 10.3967/bes2016.119.28081750
Yuan, Y; Ming, Z; Gong-Hua, H; Lan, G; Lu, D; Peng, L; Feng, J; Cai-Gao, Z. (2012a). Cr(VI) induces the decrease of ATP level and the increase of apoptosis rate mediated by ROS or VDAC1 in L-02 hepatocytes. Environ Toxicol Pharmacol 34: 579–587. 10.1016/j.etap.2012.06.016.22858589
Yuan, Y; Peng, L; Gong-Hua, H; Lu, D; Xia-Li, Z; Yu, Z; Cai-Gao, Z. (2012b). Chi-square analysis of the reduction of ATP levels in L-02 hepatocytes by hexavalent chromium. 45: 482–487. 10.1590/S0100-879X2012007500040.
Zabulyte, D; Uleckiene, S; Drebickas, V; Semaska, V; Jonauskiene, I. (2009). Investigation of combined effect of chromium (VI) and sodium fluoride in experiments on rats. Trace Elem Electroly 26: 67–71.
Zabulyte, D; Uleckiene, S; Kalibatas, J; Paltanaviciene, A; Juozulynas, A; Gocentas, A. (2006). Investigation of combined effect of chromium (VI) and nitrate in experiments on rats. Trace Elem Electroly 23: 287–291.
Zahid, ZR; Al-hakkak, ZS; Kadhim, AHH; Elias, EA; Al-jumaily, IS. (1990). Comparative effects of trivalent and hexavalent chromium on spermatogenesis of the mouse. Toxicol Environ Chem 25: 131–136. 10.1080/02772249009357512.
Zayed, A; Lytle, CM; Qian, JH; Terry, N. (1998). Chromium accumulation, translocation and chemical speciation in vegetable crops. Planta 206: 293–299.
Zendehdel, R; Shetab-Boushehri, SV; Azari, MR; Hosseini, V; Mohammadi, H. (2014). Chemometrics models for assessment of oxidative stress risk in chrome-electroplating workers. Drug Chem Toxicol 38: 1–6. 10.3109/01480545.2014.922096.24580112
Zeng, M; Xiao, F; Zhong, X; Jin, F; Guan, L; Wang, A; Liu, X; Zhong, C. (2013). Reactive oxygen species play a central role in hexavalent chromium-induced apoptosis in Hep3B cells without the functional roles of p53 and caspase-3. Cell Physiol Biochem 32: 279–290. 10.1159/000354436.23942225
Zey, JN; Lucas, C. (1985). Health hazard evaluation report no. HETA-82–358-1558, United Catalysts, Inc. South Plant, Louisville, Kentucky. (HETA-82–358-1558). Cincinnati, OH: National Institute for Occupational Safety and Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB86116951.
Zhang, B; Zhou, Y; Lin, N; Lowdon, RF; Hong, C; Nagarajan, RP; Cheng, JB; Li, D; Stevens, M; Lee, HJ; Xing, X; Zhou, J; Sundaram, V; Elliott, G; Gu, J; Shi, T; Gascard, P; Sigaroudinia, M; Tlsty, TD; Kadlecek, T; Weiss, A; O'Geen, H; Farnham, PJ; Maire, CL; Ligon, KL; Madden, PA; Tam, A; Moore, R; Hirst, M; Marra, MA; Zhang, B; Costello, JF; Wang, T. (2013). Functional DNA methylation differences between tissues, cell types, and across individuals discovered using the M&M algorithm. Genome Res 23: 1522–1540. 10.1101/gr.156539.113.23804400
Zhang, J; Wang, Y; Jiang, X; Chan, HC. (2018). Cystic fibrosis transmembrane conductance regulator-emerging regulator of cancer [Review]. Cell Mol Life Sci 75: 1737–1756. 10.1007/s00018-018-2755-6.29411041
Zhang, JD; Li, S. (1997). RETRACTED: Cancer mortality in a Chinese population exposed to hexavalent chromium in water. J Occup Environ Med 39: 315–319. 10.1097/00043764-199704000-00008.9113601
Zhang, JD; Li, XL. (1987a). [Chromium pollution of soil and water in Jinzhou]. Zhonghua Yufang Yixue Zazhi 21: 262–264.3443034
Zhang, JD; Li, XL. (1987b). Investigation and Study of Chromium Pollution in Jinzhou. Zhonghua Yufang Yixue Zazhi 21.
Zhang, R; Xiang, Y; Ran, Q; Deng, X; Xiao, Y; Xiang, L; Li, Z. (2014). Involvement of calcium, reactive oxygen species, and ATP in hexavalent chromium-induced damage in red blood cells. Cell Physiol Biochem 34: 1780–1791. 10.1159/000366378.25427846
Zhang, XH; Zhang, X; Wang, XC; Jin, LF; Yang, ZP; Jiang, CX; Chen, Q; Ren, XB; Cao, JZ; Wang, Q; Zhu, YM. (2011). Chronic occupational exposure to hexavalent chromium causes DNA damage in electroplating workers. BMC Public Health 11: 224. 10.1186/1471-2458-11-224.21481275
Zhang, XH; Zhang, X; Zhang, L; Chen, Q; Yang, Z; Yu, J; Fu, H; Zhu, YM. (2012). XRCC1 Arg399Gln was associated with repair capacity for DNA damage induced by occupational chromium exposure. BMC Research Notes 5: 263. 10.1186/1756-0500-5-263.22642904
Zhang, Y; Su, Z; Hu, G; Hong, S; Long, C; Zhang, Q; Zheng, P; Wang, T; Yu, S; Yuan, F; Zhu, X; Jia, G. (2022). Lung function assessment and its association with blood chromium in a chromate exposed population. Sci Total Environ 818: 151741. 10.1016/j.scitotenv.2021.151741.34808188
Zhang, Y; Xiao, F; Liu, X; Liu, K; Zhou, X; Zhong, C. (2017). Cr(VI) induces cytotoxicity in vitro through activation of ROS-mediated endoplasmic reticulum stress and mitochondrial dysfunction via the PI3K/Akt signaling pathway. Toxicol In Vitro 41: 232–244. 10.1016/j.tiv.2017.03.003.28323103
Zhang, Y; Zhang, Y; Xiao, Y; Zhong, C; Xiao, F. (2019). Expression of Clusterin suppresses Cr(VI)-induced premature senescence through activation of PI3K/AKT pathway. Ecotoxicol Environ Saf 183: 109465. 10.1016/j.ecoenv.2019.109465.31376806
Zhang, Y; Zhang, Y; Zhong, C; Xiao, F. (2016). Cr(VI) induces premature senescence through ROS-mediated p53 pathway in L-02 hepatocytes. Sci Rep 6(34578): 1–10. 10.1038/srep34578.28442746
Zhao, L; Song, Y; Pu, J; Guo, J; Wang, Y; Chen, Z; Chen, T; Gu, Y; Jia, G. (2014). Effects of repeated Cr(VI) intratracheal instillation on club (Clara) cells and activation of nuclear factor-kappa B pathway via oxidative stress. Toxicol Lett 231: 72–81. 10.1016/j.toxlet.2014.09.011.25240275
Zheng, W; Ge, F; Wu, K; Chen, X; Li, X; Chen, Y; Lv, Y; Lian, Q; Ge, RS. (2018). In utero exposure to hexavalent chromium disrupts rat fetal testis development. Toxicol Lett 299: 201–209. 10.1016/j.toxlet.2018.10.010.30315952
Zhitkovich, A. (2005). Importance of chromium-DNA adducts in mutagenicity and toxicity of chromium(VI) [Review]. Chem Res Toxicol 18: 3–11. 10.1021/tx049774+.15651842
Zhitkovich, A. (2011). Chromium in drinking water: sources, metabolism, and cancer risks [Review]. Chem Res Toxicol 24: 1617–1629. 10.1021/tx200251t.21766833
Zhitkovich, A; Lukanova, A; Popov, T; Taioli, E; Cohen, H; Costa, M; Toniolo, P. (1996a). DNA-protein crosslinks in peripheral lymphocytes of individuals exposed to hexavalent chromium compounds. Biomarkers 1: 86–93. 10.3109/13547509609088675.23888918
Zhitkovich, A; Song, Y; Quievryn, G; Voitkun, V. (2001). Non-oxidative mechanisms are responsible for the induction of mutagenesis by reduction of Cr(VI) with cysteine: role of ternary DNA adducts in Cr(III)-dependent mutagenesis. Biochemistry 40: 549–560. 10.1021/bi0015459.11148050
Zhitkovich, A; Voitkun, V; Costa, M. (1996b). Formation of the amino acid-DNA complexes by hexavalent and trivalent chromium in vitro: importance of trivalent chromium and the phosphate group. Biochemistry 35: 7275–7282.8679557
Zhitkovich, A; Voitkun, V; Kluz, T; Costa, M. (1998). Utilization of DNA-protein cross-links as a biomarker of chromium exposure. Environ Health Perspect 106 Suppl 4: 969–974.9703480
Zhong, X; de Cássia da Silveira E Sá, R; Zhong, C. (2017a). Mitochondrial biogenesis in response to chromium (VI) toxicity in human liver cells. International Journal of Molecular Sciences 18. 10.3390/ijms18091877.
Zhong, X; Yi, X; da Silveira E Sá, RC; Zhang, Y; Liu, K; Xiao, F; Zhong, C. (2017b). CoQ10 Deficiency May Indicate Mitochondrial Dysfunction in Cr(VI) Toxicity. International Journal of Molecular Sciences 18. 10.3390/ijms18040816.
Zhong, X; Zeng, M; Bian, H; Zhong, C; Xiao, F. (2017c). An evaluation of the protective role of vitamin C in reactive oxygen species-induced hepatotoxicity due to hexavalent chromium in vitro and in vivo. J Occup Med Toxicol 12: 12. 10.1186/s12995-017-0161-x.28559919
Zhou, W; Yu, T; Vazin, M; Ding, J; Liu, J. (2016). Cr(3+) binding to DNA backbone phosphate and bases: Slow ligand exchange rates and metal hydrolysis. Inorg Chem 55: 8193–8200. 10.1021/acs.inorgchem.6b01357.27478904
Zhu, L; Li, X; Yuan, Y; Dong, C; Yang, M. (2021). APC promoter methylation in gastrointestinal cancer [Review]. Front Oncol 11: 653222. 10.3389/fonc.2021.653222.33968756
Ziliak, ST. (2011). Matrixx v. Siracusano and Student v. Fisher. Significance 8: 131–134.
Zuo, Z; Cai, T; Li, J; Zhang, D; Yu, Y; Huang, C. (2012). Hexavalent chromium Cr(VI) up-regulates COX-2 expression through an NFκB/c-Jun/AP-1-dependent pathway. Environ Health Perspect 120: 547–553. 10.1289/ehp.1104179.22472290