# AUTHORS | CONTRIBUTORS | REVIEWERS

## Assessment Managers (Lead Authors)

Catherine F. Gibbons, PhD; Alan F. Sasso, PhD (to October 2023) | EPA/ORD/CPHEA

## Assessment Team (Authors)

Michelle M. Angrish, PhD; Xabier Arzuaga, PhD; Thomas F. Bateson, MPH, ScD; Krista Yorita Christensen, MPH, PhD; Johanna Congleton, MSPH, PhD; Barbara Glenn, PhD (retired); Leonid Kopylev, PhD; David Lehmann, PhD; Roman F. Mezencev, PhD; Rebecca M. Nachman, MPH, PhD; Kathleen Newhouse, MS; Elizabeth G. Radke, MPH, PhD; Paul Reinhart, PhD; Susan Rieth, MPH (retired); Paul M. Schlosser, PhD; Rachel M. Shaffer, MPH, PhD; Andre Weaver, PhD; Amina Wilkins, MS (retired); Erin E. Yost, PhD | EPA/ORD/CPHEA

## Contributors

Ted Berner, MS (retired); Todd Blessinger, PhD; Christine Cai, MS; Glinda Cooper, PhD (former); Jeffry Dean, PhD; Stephanie Kim, MS (former); Urmila Kodavanti; Alexandra Larsen, PhD; Cheng-Kuan (Calvin) Lin; Larissa Pardo, MS (former); Todd Zurlinden, PhD | EPA/ORD/CPHEA
Keith Salazar, PhD; Sabah Tariq | EPA/ORD/OCSPP
Stephanie Smith-Roe | NIH/NIEHC/NTP
Nora Abdel-Gawad (former); Kelly Garcia (former); Carolyn Gigot (former); Andrew Greenhalgh (former); Shahreen Hussain (former); Grace Kaupas (former, currently OCSPP) | Oak Ridge Associated Universities (ORAU) Contractor

## Production Team

Jack Rehmann (CPHEA Webmaster); Ryan Jones (HERO Director); Dahnish Shams (Project Management Team); Avanti Shirke (Project Management Team); Jessica Soto-Hernandez (Project Management Team); Samuel Thacker (HERO Team); Garland Waleko (Project Management Team) | EPA/ORD/CPHEA
Rebecca Schaefer (Project Management Team) | Oak Ridge Associated Universities (ORAU) Contractor

## Contractor Support

Michelle Cawley; Ali Goldstone; Kim Osborn; Alessandria Schumacher; Nicole Vetter | ICF, Inc.

## Executive Direction

Wayne Cascio, MD (CPHEA Director); V. Kay Holt, MS (CPHEA Deputy Director); Samantha Jones, PhD (CPHEA Associate Director); Kristina Thayer, PhD (CPAD Director); Andrew Kraft, PhD (CPAD Associate Director); Paul White, MS (CPAD Senior Science Advisor); Ravi Subramanian, PhD (CPAD Science Advisor); Elizabeth Radke, PhD (Branch Chief); Janice Lee, PhD (Branch Chief); Viktor Morozov, PhD (Branch Chief); Shannon Hanna, PhD (Branch Chief); Glenn Rice, PhD (Branch Chief); Vicki Soto, BS (Branch Chief) | EPA/ORD/CPHEA

## Reviewers

CPAD Executive Review Committee
Kris Thayer | CPAD Division Director
Andrew Kraft | CPAD Associate Director
Paul White | CPAD Senior Science Advisor
Todd Zurlinden | CPAD Senior Scientist
Todd Blessinger | CPAD Senior Scientist
Krista Christensen | CPAD Senior Scientist
Ila Cote | U.S. EPA (retired), Contractor
Alan Stern | NJDEP (retired), Contractor
Epidemiology Workgroup
General Toxicity/Immunotoxicity/Cancer Workgroup
Pharmacokinetics Workgroup
Reproductive/Developmental/Neurotoxicity Workgroup
Statistics Workgroup
Systematic Review Workgroup
Toxicity Pathways/Genotoxicity Workgroup
Agency Reviewers
This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:
Office of the Administrator/Office of Children’s Health Protection
Office of Air and Radiation/Office of Air Quality Planning and Standards
Office of Chemical Safety and Pollution Prevention
Office of Land and Emergency Management
Office of Water
Region 2, New York City, NY
Region 3, Philadelphia, PA
Region 4, Atlanta, GA
Region 8, Denver, CO
Interagency Reviewers
This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). Comments were submitted by:
The White House
Office of Science and Technology Policy
Office of Management and Budget
Department of Agriculture
Department of Defense
Department of Health and Human Services
Agency for Toxic Substances and Disease Registry
National Institute of Environmental Health Sciences
National Institute of Occupational Safety and Health

This assessment was released for public comment on October 20, 2022, and comments were due on December 19. 2022. The public comments are available on Regulations.gov in Docket EPA-HQ-ORD-2014–0313. A summary and EPA’s disposition of the comments received is included in Appendix G.

This assessment was peer reviewed by independent, expert scientists external to EPA convened by the EPA Science Advisory Board (SAB). Peer-review meetings were held on February 15, 2023; March 29–31, 2023; July 19–27, 203; and September 21–22, 2023. The report of the review of the EPA’s Draft Toxicological Review of Hexavalent Chromium, dated September 27, 2023, is available on the IRIS website. A summary and EPA’s disposition of the comments received is included in Appendix G.