# 4 DOSE-RESPONSE ANALYSIS

## 4.1 ORAL REFERENCE DOSE FOR EFFECTS OTHER THAN CANCER

The RfD (expressed in units of mg/kg-day) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from points of departure (PODs) such as a no-observed-adverse-effect level (NOAEL), lowest-observed-adverse-effect level (LOAEL), or the 95% lower bound on the benchmark dose (BMDL), with uncertainty factors (UFs) generally applied to reflect limitations of the data used.

As discussed in Sections 3.2.2, 3.2.4, 3.2.5, and 3.2.9, based on findings in experimental animals, the evidence indicates that exposure to Cr(VI) is likely to cause GI, liver, and developmental toxicity in humans. Because the totality of available evidence was sufficient to indicate that exposure to Cr(VI) has the potential to cause these health effects, organ/system-specific reference values were derived for GI, liver, and developmental toxicity, and not for most health effects with evidence integration judgments of evidence suggests (i.e., male reproductive effects and immune toxicity). However, for hematological effects, it was determined that a toxicity value derived for short-term/subchronic exposures may be useful to protect susceptible populations (such as individuals with pre-existing anemia, including pregnant women). More details are provided in Section 3.3.2.5. An overview of the process for deriving candidate values, osRfDs and osRfCs and overall RfDs and RfCs is provided in Appendix Figure D-1. Noncancer dose response data are presented in Appendix D.1.

### 4.1.1 Prioritization of Studies for Dose-Response Analysis of Selected Effects

In order to prioritize the studies for dose-response analysis (see Figure 4-1), key attributes of the studies reporting the endpoints selected for each hazard were reviewed (i.e., study size and design, relevance of the exposure paradigm, and measurement of the endpoints of interest). Exposure paradigms including a relevant route of human environmental exposure are preferred. When developing a chronic reference value, chronic or subchronic studies are preferred over studies of acute exposure durations (with the exception of developmental studies, where exposures only need to occur during susceptible periods). Studies with a broad exposure range and multiple exposure levels are preferred to the extent that they can provide information about the shape of the exposure-response relationship.

Human studies are generally preferred over animal studies as the basis for a reference value when quantitative measures of exposure are reported, and the reported effects are determined to be associated with exposure. The available epidemiological studies of worker populations exposed to Cr(VI) examined the relationship between certain health endpoints and inhalation exposure; however, no sufficient epidemiological studies of ingested Cr(VI) are available and route-to-route extrapolation was not considered for this assessment (see Protocol, Appendix A). In the absence of human data, the animal studies were considered for dose-response analysis.

Experimental animal studies considered for each health effect were evaluated using general study evaluation considerations discussed in the Protocol (see Appendix A). The oral animal toxicological evidence base for Cr(VI) consists of chronic and subchronic studies. Because medium and high confidence studies were available, low confidence studies were not considered for toxicity value derivation.

Cr(VI) can induce frank effects in rodents at high doses, which raises considerations of exposures and study designs appropriate for dose-response analysis. Because Cr(VI) gavage exposure has been shown to induce frank effects and high mortality in rodents (gut detoxification is much less effective for gavage exposure), these studies were not considered for dose-response assessment. This criterion resulted in the omission of one high confidence study (Zheng et al., 2018) from consideration of dose-response analysis for developmental effects. High dose exclusion criteria for drinking water and oral feed studies were also considered. At approximately 20 mg/kg-day ad libitum, NTP (2007) reported reduced body weight, chemical-induced stomach ulcers (80%–100% incidence), and reduced water consumption in rats exposed for 90 days. The study also reported 10%–20% decreases in final body weight relative to controls in mice exposed for 90 days at the high doses (approximately 15–25 mg/kg-day). In order to focus on chronic effects observed in the low dose region (defined here as around 1 mg/kg-day ad libitum based on results observed by the chronic 2-year NTP (2008) drinking water bioassay), studies which did not include an exposed group below 20 mg/kg-day were not considered for RfD derivation. This criterion ultimately did not impact any decisions regarding dose-response, because all such studies were rated low confidence.

Figure 4-1 Prioritization of studies from the Cr(VI) hazard identification for derivation of toxicity values.

For endpoints where medium or high confidence studies were available, low confidence studies were not considered.

#### 4.1.1.1 GI Tract Toxicity

Small intestine histopathology was considered for dose-response analysis of the GI tract effects of oral exposure to Cr(VI). Chronic data from the NTP (2008) 2-year bioassay were used for the dose-response assessment. The chronic 2-year NTP (2008) bioassay analyzed many of the same endpoints as other shorter-term studies (which had smaller sample sizes and typically used higher doses). Thompson et al. (2011); (2012b) were subchronic studies which incorporated lower doses than NTP (2008). These studies used smaller sample sizes and shorter exposure durations than NTP (2008), and only examined females (see Table 4-1). An overview of design features of the high confidence animal studies containing data for the GI tract is provided below in Table 4-1.

Table 4-1 Design features of high confidence studies that examined GI tract effects (histopathology) via the oral route of exposure

Study reference | Species/strain and sex | Exposure duration | Number of dose groups^a^ | Number of animals/group | Dose range (mg/kg-d)
NTP (2008) ^b^ | B6C3F1 mouse, male and female | 2 yr | 4 | 50 | 0.3–8.9
NTP (2008) | F344 Rat, male and female | 2 yr | 4 | 50 | 0.2–7.1
NTP (2007) | F344 Rat, male and female | 90 d | 5 | 10 | 1.7–21
NTP (2007) | B6C3F1 mouse, male and female | 90 d | 5 | 10 | 3.1–27.9
NTP (2007) | B6C3F1 mouse, male | 90 d | 3 | 5 | 2.8–8.7
NTP (2007) | BALB/c mouse, male | 90 d | 3 | 5 | 2.8–8.7
NTP (2007) | am-C57BL/6 mouse, male | 90 s | 3 | 5 | 2.8–8.7
Thompson et al. (2012b) | F344 Rat, female | 90 d^c^ | 5 | 10 | 0.015–20
Thompson et al. (2011) | B6C3F1 mouse, female | 90 d^c^ | 6 | 10 | 0.024–31.1

a Number does not include control group.

b Preferred data for dose-response.

c Note: Thompson et al. (2012b) and Thompson et al. (2011) also performed an 8-day sacrifice on 5 animals/group.

The most sensitive GI effect in mice, diffuse epithelial hyperplasia, was consistently observed at statistically significant incidence levels in mice in all exposure groups (≥0.3 mg/kg-day Cr(VI)) of males and females of multiple strains in three high confidence subchronic and chronic studies (Thompson et al., 2011; NTP, 2007, 2008). The hyperplastic duodenal lesions were described as being suggestive of tissue regeneration following degenerative changes to the intestinal villi. In rats, it was observed less consistently and at higher doses compared with mice (Thompson et al., 2011; 2012b; Cullen et al., 2015). Dose-response modeling was performed on the chronic 2-year data for male and female mice from NTP (2008) exhibiting diffuse epithelial hyperplasia of the proximal small intestine (duodenum). For comparative purposes, dose-response modeling was also performed on the 90-day GI tract endpoints in mice from Thompson et al. (2011) and NTP (2007) (n = 10 study), as well as the data for hyperplasia in the duodenum of female rats exposed for 90 days (Thompson et al., 2012b).

#### 4.1.1.2 Hepatic Toxicity

Liver histopathology changes and serum biomarkers of liver injury were considered for dose-response analysis of the hepatic effects of oral exposure to Cr(VI). These were considered the most representative indicators of hepatic toxicity in the database. Fatty liver changes (cytoplasmic vacuolation) and increased ALT are also clinical markers used in diagnosis of human liver diseases (see Section 3.3). Dose-response modeling was not performed on liver weight because only moderate changes were observed (see Section 3.2.4), and changes in liver histopathology and serum biomarkers were more consistently observed and more sensitive than liver weight changes.

Generally consistent elevations of ALT (biomarkers of liver injury) were seen across various multiple well-conducted studies in both rats and mice, with the magnitude of change considered to be biologically significant and a specific indication of liver damage. For dose-response modeling of clinical chemistry changes, NTP (2008) observed increased alanine aminotransferase (ALT) in male F344 rats at all three data collection time points (3, 6, and 12 months). Dose-response modeling was performed on the clinical chemistry endpoint ALT in male F344 rats^64^ at the 12-month and 90-day collection periods of the NTP (2008) bioassay. ALT changes in male and female rats from the 90-day NTP (2007) study were also modeled.^65^ ALT changes in male rats at the 90-day timepoint from the 2-year NTP (2008) study were modeled to provide a comparison with the 90-day NTP (2007) data. In mice, changes in ALT only occurred at high doses during the 90-day NTP (2007), and there were no changes in the other clinical chemistry parameters like there were in rats. Therefore, this endpoint was not modeled in mice.

For histopathological changes, increased incidence of chronic liver inflammation was observed in rodents during the 2-year NTP (2008) bioassay, but this endpoint exhibited a monotonic dose-response relationship for female rats and mice. In male rats, the increased inflammation was nonmonotonic and only significantly increased for one dose group. In male mice, no effect was observed. Fatty liver changes were also observed in female rats during the 2-year NTP (2008) bioassay. Similar to the chronic inflammation endpoint, this effect was not consistently observed across species or sex. Dose-response modeling was performed on the incidence data for chronic liver inflammation and fatty liver changes in female rats from NTP (2008), and chronic inflammation in female mice from NTP (2008).

An overview of design features of the medium and high confidence animal studies containing data for hepatic effects considered for oral dose-response is provided below in Table 4-2. Because there were studies that were rated high and medium for endpoints within this domain (see Section 3.2.4), low confidence studies were not considered for dose-response assessment.

Table 4-2 Design features of studies that examined hepatic effects (clinical chemistry and histopathology) via the oral route of exposure

Study reference (quality) | Species/strain and sex | Exposure duration | Number of dose groups^a^ | Number of animals/group | Dose range (mg/kg-d)
NTP (2008) (high)^b^ | F344 Rat, male and female | 2 yr | 4 | 50 | 0.2–7.1
NTP (2008) (high)^a^ | B6C3F1 mouse, male and female | 2 yr | 4 | 50 | 0.3–8.9
NTP (2007) (high)^a^ | F344 Rat, male and female | 90 d | 5 | 10 | 1.7–21
NTP (2007) (high) | B6C3F1 mouse, male and female | 90 d | 5 | 10 | 3.1–27.9
NTP (2007) (high) | B6C3F1 mouse, male | 90 d | 3 | 5 | 2.8–8.7
NTP (2007) (high) | BALB/c mouse, male | 90 d | 3 | 5 | 2.8–8.7
NTP (2007) (high) | am-C57BL/6 mouse, male | 90 d | 3 | 5 | 2.8–8.7
Navya et al. (2017a) (high) | Wistar rat, male | 28 d | 1 | 6 | 10.6
Rafael et al. (2007) (medium) | Wistar rat, male | 10 wk | 1 | 9 control, 19 exposed | 2.96
NTP (1996a) (high) | BALB/c mouse, male and female | 9 wk | 4 | 24 males, 48 females (5–6 males, 12 females/group per timepoint) | 1.1–48.4
NTP (1997) (high) | BALB/c mouse, male and female | 13 wk continuous breeding | 3 | 20 (F0), 5–10 (offspring) | 6.8–50
Krim et al. (2013) (medium) | Wistar rat, male | 30 | 1 | 10 | 5.3
NTP (1996b) (high) | Sprague-Dawley rat, male and female | 9 wk | 4 | 5 | 0.35–9.90
Wang et al. (2015) (medium) | Sprague-Dawley rat, male | 4 wk | 3 | 8 | 2.5–7.6

a Number does not include control group.

b Preferred data for dose-response.

In summary, dose-response modeling was performed on the following hepatic datasets:

- Increased ALT in male rats from NTP (2008) at the 90-day timepoint and 12-month timepoint
- Increased ALT in male and female rats from NTP (2007) (90 days)^66^
- Increased chronic liver inflammation in female rats from NTP (2008) (2 years)
- Increased chronic liver inflammation in female mice from NTP (2008) (2 years)
- Fatty liver change in female rats from NTP (2008) (2 years)

#### 4.1.1.3 Developmental Toxicity

As noted in Section 3.2.9, decreases in fetal and postnatal growth were the only consistently observed effects observed in exposed animals. The two medium to high confidence studies that observed this effect were NTP (1997) and Zheng et al. (2018). De Flora et al. (2006) did not observe this effect. The high confidence study by Zheng et al. (2018) was not considered for dose-response assessment because it was a gavage study; Cr(VI) gavage exposure has been shown to induce frank effects and high mortality in rodents due to less effective gut detoxification compared with drinking water exposure. Dose-response modeling was performed on fetal and postnatal growth outcomes in the F1 generation observed by NTP (1997). Data are available for males (PND14 and PND21) and females (PND14 and PND21).

#### 4.1.1.4 Hematological Toxicity

The database of hematological endpoints is extensive due to the number of studies reporting these endpoints and the comprehensive measures available for multiple markers from complete blood counts (i.e., MCV, MCH, MCHC, Hgb, and Hct) (see Section 3.2.5). There are eleven datasets from six high confidence NTP studies, and five medium confidence datasets from NTP and other sources. Data from NTP (2008) and NTP (2007) were particularly useful because they collected data at multiple timepoints. An overview of the design features of these studies is presented above in Table 4-2. Because hemoglobin (Hgb) is essential for the transport of oxygen molecules, it is the marker most closely associated with adverse outcomes caused by iron-deficient anemia. Because the hematological effects ameliorated over time, the dose-response will focus on subchronic and short-term data (90 days and 22 days), with chronic data at 12 months used as a comparison. Only the rat data were modeled, since little or no effects were observed in mice. While the most sensitive low-dose data were at 22 days from NTP (2008) (which used lower doses than NTP (2007)), dose response data from the 2007 study were still evaluated to assess possible sex differences (the 2008 study only collected hematological data in male rats and female mice). The use of 22-day data for the POD (as opposed to the 12-month data when effects ameliorated) was determined to be appropriate in order to protect susceptible subpopulations (such as individuals with pre-existing anemia, including pregnant women; see Section 3.3.1) from both short-term and chronic health effects.

In summary, dose-response modeling was performed on the following hematological datasets:

- Decreased Hgb in male rats from NTP (2008) at 22 days, 90 days, and 12 months
- Decreased Hgb in male and female rats from NTP (2007) at 23 days, and 90 days

### 4.1.2 Methods of Analysis

Biologically based dose-response models are not available for Cr(VI). In this situation, EPA evaluates a range of dose-response models thought to be consistent with underlying biological processes to determine how best to empirically model the dose-response relationship in the range of the observed data. Consistent with this approach, EPA evaluated dose-response information with the models^67^ available in EPA’s Benchmark Dose Software (BMDS, Version 3.2). EPA estimated the benchmark dose (BMD) and the 95% lower confidence limit on the BMD (BMDL) using a benchmark response (BMR) that represents a minimal, biologically significant level of change (U.S. EPA, 2012b). Endpoint-specific BMRs are described below. Where modeling was feasible, the estimated BMDLs were used as points of departure (PODs); the PODs are summarized in Table 4-3. Further details including the modeling output and graphical results for the model selected for each endpoint can be found in Appendix D.1 and (U.S. EPA, 2021a). Where dose-response modeling was not feasible, no-observed-adverse-effect levels (NOAELs) or lowest-observed-adverse-effect levels (LOAELs) were identified; NOAELs and LOAELs are also summarized in Table 4-3.

#### 4.1.2.1 PBPK Modeling and Animal-to-Human Extrapolation

Following ingestion, extracellular reduction of Cr(VI) to Cr(III) in the stomach is a major pathway for detoxification in both rodents and humans and may have a significant impact on the amount of Cr(VI) available for absorption and distribution. Uptake of Cr(VI) into tissues and intracellular reduction occurs rapidly (see Section 3.1.1 and Appendix C.1.1 for overview). While GI tract PBPK models are capable of estimating the extent of extracellular reduction in the stomach, the in vivo estimates of localized uptake and reduction of Cr(VI) in GI and systemic tissues exhibit high uncertainties (particularly for the distal GI). Thus, all unreduced Cr(VI) that escapes stomach reduction and enters the small intestine (estimated by PBPK modeling) is assumed to have the potential for absorption into epithelial cells. The unreduced mg/kg-day Cr(VI) dose escaping stomach reduction in the rodent can be adjusted to an internal dose^68^ by allometric scaling consistent with Recommended Use of Body Weight^3/4^ as the Default method in derivation of the oral reference dose (U.S. EPA, 2011c). While there is some uncertainty in how much of the unreduced Cr(VI) escaping the stomach is reduced and absorbed by the GI tissue prior to systemic distribution, the interspecies difference in this amount is likely to be low in relation to the interspecies difference in gastric reduction (which is driven by differences in stomach pH and Cr(VI) reduction capacity).

PBPK modeling revealed that the Cr(VI) dose escaping stomach reduction (and therefore the internal dose) increased linearly with oral dose for rats and mice (see Appendix C.1.5). Therefore, performing BMD modeling on the orally administered doses and performing PK conversions at a later step would ultimately produce the same POD as if BMD modeling was performed on the basis of internal PK-derived rodent doses. For humans, gastric reduction is nonlinear with respect to ingested dose (see Appendix C.1.5).

The steps for candidate value derivation are outlined below and in Figure 4-2:

- Dose-response modeling was performed on the basis of mg/kg-day Cr(VI) ingested to determine a BMDL or LOAEL/NOAEL. Where possible, time-weighted average daily doses calculated from time-course data (through the time of data collection) were used. For example, for endpoints only measured at the 12-month time point in a 2-year study, the time-weighted average daily doses over 12 months were used for dose-response (as opposed to the average daily doses over the full 2-year study).
- The BMDL or LOAEL/NOAEL (in units of mg/kg-day Cr(VI)) was converted to an internal dose using the PK model. The internal dose was the average rodent dose escaping reduction (in mg/kg-day) multiplied by (BW_A_/BW_H_)^1/4^ in accordance with Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c). Study-specific time-weighted average body weights relevant to the data collection time were used in the model and for the BW scaling step. The BW scaling step is necessary to account for interspecies differences in the distribution of Cr(VI) dose across different small intestine surface areas or volumes. Because organ volumes and surface areas vary between species by allometric relationships, alternative dose metrics that use volume or surface area as a normalizing factor produce similar PODs as BW scaling. See Appendix C.1.5.1.
- The adult-based human PBPK model was used to estimate the daily mg/kg Cr(VI) dose that must be ingested to achieve the internal dose calculated in step (2). To account for
- interindividual variability, the human equivalent dose was determined by Monte Carlo analysis. The lower 1% value of 20000 Monte Carlo PK simulations needed to achieve the internal dose POD was used. As a result, the intraspecies uncertainty factor (UF_H_) was lowered from 10 to 3 (the pharmacokinetic component of the uncertainty factor was removed as it was accounted for with this analysis). See Appendix C.1.5.
- The uncertainty factors are applied to derive the candidate values.

Figure 4-2 Process for calculating the human equivalent dose for Cr(VI).

#### 4.1.2.2 GI Tract Effects

Incidence data of diffuse epithelial hyperplasia of the duodenum in male mice from NTP (2008) were amenable to BMD modeling with the highest dose omitted. A BMR of 10% extra risk (ER) was applied under the assumption that it represents a minimally biologically significant level of change in the absence of a biologically based BMR (U.S. EPA, 2012b). Diffuse epithelial hyperplasia, although predictive of more severe manifestations of toxicity, is itself considered to be of minimal severity and does not support using a lower BMR. Incidence data for male mice (all doses included) are contained in HAWC (https://hawc.epa.gov/ani/endpoint/27488/).

Diffuse epithelial hyperplasia was not amenable to BMD modeling for female mice (https://hawcprd.epa.gov/ani/endpoint/27486/) because there was too much uncertainty in estimating the BMDL (see Appendix D.1.1). There were three models which adequately fit the data in accordance with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012b). However, they produced significantly different BMDs and BMDLs, and one model did not produce useful results due to an extremely low BMDL estimate and high BMD:BMDL ratio. This is an indication that there was some model dependence of the estimates, and uncertainty in the estimates was too great to be able to rely on the modeling results. The uncertainty was primarily caused by the fact that the observed percent incidence at the lowest dose (38%) was much higher than the BMR (10%). Because there are no data near where the true 10% response occurs, estimating the BMD_10_ and the 95% lower confidence limit on the BMD_10_ is highly uncertain. Alternative modeling approaches were explored; however, they could not address the lack of low dose data near the target 10% extra risk response level. As a result, the LOAEL approach was used (the LOAEL for hyperplasia in female mice was 0.302 mg/kg-day). Incidence data for female mouse hyperplasia in the duodenum are available in HAWC (https://hawc.epa.gov/ani/endpoint/27486/).

#### 4.1.2.3 Hepatic Effects

For the liver, data for chronic liver inflammation (https://hawc.epa.gov/ani/endpoint/100000137/) in female mice from NTP (2008) were amenable to BMD modeling. A BMR of 10% extra risk (ER) was applied under the assumption that it represents a minimally biologically significant level of change. NTP (2008) described these lesions as “minimal to mild severity,” with “mild to moderate” in the higher dose groups. As a result, a BMR lower than 10% was not considered.

Changes in the liver enzyme alanine aminotransferase (ALT) (https://hawc.epa.gov/ani/endpoint/100000139/) at 12 months in male rats from NTP (2008) were amenable to BMD modeling. Several expert organizations, particularly those concerned with early signs of drug-induced hepatotoxicity, have identified an increase in liver enzymes compared with concurrent controls of two to fivefold as an indicator of concern for hepatic injury (Sawicka and Długosz, 2017; Group, 2000; EMEA, 2010; Boone et al., 2005). For this assessment, a twofold increase in ALT is considered indicative of liver injury in experimental animals. Thus, a BMR of 100% change from control (1 relative deviation from control) was applied. Data for male and female rats in the subchronic study by NTP (2007) were not amenable to BMD modeling,^69^ and the lowest dose was identified as the LOAEL. The chronic study by NTP (2008) also provides subchronic data for ALT (https://hawc.epa.gov/ani/endpoint/100502465/) in male rats at 90 days. Because the chronic study used lower doses, it was possible to identify a NOAEL^70^ of 1.58 mg/kg-day, and a LOAEL of 4.16 mg/kg-day for increased ALT in male rats at 90 days (see Appendix C.1.5 for time-weighted average daily doses of the first 90 days of exposure during the NTP (2008) 2-year study).

Fatty liver change (https://hawc.epa.gov/ani/endpoint/100000136/) in female rats from NTP (2008) was not amenable to BMD modeling. Similar to hyperplasia in the female mouse duodenum, uncertainty in estimating the BMDL was too high (see Appendix D.1.1). As a result, the NOAEL (the lowest dose level, 0.248 mg/kg-day, which exhibited less than 10% extra risk) was used as the POD for this dataset. Similarly, chronic liver inflammation (https://hawc.epa.gov/ani/endpoint/100000135/) in female rats from NTP (2008) was not amenable to BMD modeling because uncertainty in estimating the BMDL was too high (see Appendix D.1.1), and the LOAEL (0.248 mg/kg-day, which exhibited greater than 10% extra risk) was used as the POD.

#### 4.1.2.4 Developmental Effects

For NTP (1997), doses reported for the F0 dams^71^ were 11.6, 24.4, and 50.6 mg/kg-day Cr(VI) (via feed). Decreased postnatal growth in the F1 generation was observed beginning at 24.4 mg/kg-day. Data are available for males (PND14 (https://hawcprd.epa.gov/ani/endpoint/100535280/) and PND21 (https://hawc.epa.gov/ani/endpoint/100535281/)) and females (PND14 (https://hawc.epa.gov/ani/endpoint/100535278/) and PND21 (https://hawcprd.epa.gov/ani/endpoint/100535279/)). For postnatal growth in the F2 generation, effects were observed at the highest dose only (maternal doses for females in the F1 generation were 7.27, 17.19, 39.15 mg Cr(VI)/kg-day). Datasets for postnatal growth were not amenable to BMD modeling because study statistics reported by the authors were inadequate for use in multi-generational modeling.^72^ A NOAEL of 11.6 mg/kg-day was used based on outcomes observed in the F1 generation (see Section 3.2.9).

#### 4.1.2.5 Hematological Effects

Male rat data of decreased Hgb at 22 days (https://hawc.epa.gov/ani/endpoint/100001936/) from NTP (2008) was amenable to BMD modeling using a BMR of 1 standard deviation from the mean.^73^ These data exhibited the most sensitive response, and also contained the lowest dose range. With the exception of male rat data at 90 days from NTP (2007) (which was also amenable to BMD modeling), all other datasets required a LOAEL/NOAEL analysis. All available hematological data considered for dose-response modeling are available in Appendix D.1.

### 4.1.3 Derivation of Candidate Values

This section describes the data and rationale for the selection of uncertainty factors and derivation of candidate values for each identified human health hazard. The dose-response modeling results and rodent-to-human extrapolations are summarized in Table 4-3. Further details, including the BMDS modeling output and graphical results for the model selected for each endpoint, can be found in Appendix D.1.

Table 4-3 Summary of derivation of points of departure following oral exposure

Species/sex | Model | BMR | BMD mg/kg-d | BMDL or LOAEL/NOAEL mg/kg-d | Internal dose^a^ mg/kg-d | TWA BW kg | BW^3/4^ adjust^b^ mg/kg-d | POD_HED_ mg/kg-d^c^
Diffuse epithelial hyperplasia of the duodenum at 2 yr ( NTP, 2008 )
Mice/M | Quantal linear^d^ | 10% ER | 0.148 | 0.121 | 0.0182 | 0.05 | 2.88 × 10^−3^ | 0.0443
Mice/F | LOAEL | – | – | 0.302 | 0.0463 | 0.05 | 7.32 × 10^−3^ | 0.0911
Diffuse epithelial hyperplasia of the duodenum at 90 d ( NTP, 2007 )
Mice/M | Quantal linear | 10% ER | 0.454 | 0.314 | 0.0479 | 0.025 | 6.37 × 10^−3^ | 0.0831
Mice/F | LOAEL | – | – | 3.1 | 0.582 | 0.025 | 0.0774 | 0.267
Crypt cell hyperplasia of the duodenum at 90 d ( Thompson et al., 2011 )
Mice/F | NOAEL | – | – | 4.6 | 0.934 | 0.022 | 0.120 | 0.331
Villous cytoplasmic vacuolization of the duodenum at 90 d ( Thompson et al., 2011 )
Mice/F | NOAEL | – | – | 1.1 | 0.179 | 0.022 | 0.0231 | 0.154
Hyperplasia of the duodenum at 90 d (Thompson et al., 2012b)
Rat/F | NOAEL | – | – | 2.9 | 0.375 | 0.155 | 0.0787 | 0.270
Increase in the liver enzyme alanine aminotransferase (ALT) ( NTP, 2008 )
Rat/M 12 mo | Expon.2 ^d^ | 1RD | 1.83 | 1.56 | 0.170 | 0.395 | 0.0451 | 0.204
Rat/M 3 mo | NOAEL | – | – | 1.58 | 0.165 | 0.246 | 0.0389 | 0.191
Increase in the liver enzyme alanine aminotransferase (ALT) at 90 d ( NTP, 2007 )
Rat/M | LOAEL | – | – | 1.74 | 0.188 | 0.232 | 0.0436 | 0.203
Rat/F | LOAEL | – | – | 1.74 | 0.181 | 0.160 | 0.0383 | 0.190
Chronic liver inflammation at 2 yr ( NTP, 2008 )
Rat/F | LOAEL | – | – | 0.248 | 0.0195 | 0.260 | 4.66 × 10^−3^ | 0.0669
Mice/F | Log-logistic | 10% ER | 3.70 | 1.33 | 0.225 | 0.05 | 0.0356 | 0.182
Liver fatty change at 2 yr ( NTP, 2008 )
Rat/F | NOAEL | – | – | 0.248 | 0.0195 | 0.260 | 4.66 × 10^−3^ | 0.0669
Decreased offspring growth ( NTP, 1997 )
Mouse/F | NOAEL | – | – | 11.6 | 3.09 | 0.0240 | 0.407 | 0.700
Decrease in hemoglobin (Hgb) NTP (2008)
Rat/M 22 d | Exp-4 | 1SD | 1.07 | 0.816 | 0.0705 | 0.138 | 0.0144 | 0.126
Rat/M 3 mo | NOAEL | – | – | 1.58 | 0.165 | 0.246 | 0.0389 | 0.191
Rat/M 12 mo | NOAEL | – | – | 2.49 | 0.336 | 0.395 | 0.0891 | 0.286
Decrease in hemoglobin (Hgb) NTP (2007)
Rat/M 90d | Exp-3 | 1SD | 2.99 | 2.09 | 0.243 | 0.232 | 0.0564 | 0.227
Rat/M 23d | LOAEL | – | – | 2.92 | 0.367 | 0.120 | 0.0722 | 0.259
Rat/F 90d | NOAEL | – | – | 3.50 | 0.500 | 0.160 | 0.106 | 0.312
Rat/F 23d | LOAEL | – | – | 2.97 | 0.370 | 0.105 | 0.0704 | 0.187

a Dose escaping stomach reduction in rodent (mg/kg-d) estimated by PK modeling. Animal BW set to study/sex-specific time-weighted average values for PK modeling. This explains the discrepancy in internal doses between male and female rats having the same external-dose LOAEL for ALT changes at 90 days, and differences between male rats at 3 months and 12 months.

b BW^3/4^ scaling adjustment: mg/kg-d multiplied by (BW_A_/80)^1/4^). Animal BW set to study/sex-specific time-weighted average (TWA) values for both BW^3/4^ scaling and bioassay PK simulation.

c POD_HED_ in units of mg/kg-d Cr(VI) oral dose ingested by humans (lower 1% value of 20,000 Monte Carlo PK simulations needed to achieve the internal dose POD). See Appendix C.1.5 for details.

d Data were amenable to BMD modeling with the highest dose omitted.

For BW^3/4^ scaling adjustment and PBPK modeling applied above, the mean body weight recommended by EPA’s Exposure Factors Handbook (U.S. EPA, 2011a) (80 kg) was used. There is a negligible difference in the PODs when using 70 kg (U.S. EPA, 1988) or 80 kg, and the final reference value would be the same under either assumption.

Consistent with EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002), a series of five UFs were applied to the POD developed for each endpoint/study, specifically addressing the following areas of uncertainty: interspecies uncertainty (UF_A_) to account for animal-to-human extrapolation, and consisting of equal parts representing pharmacokinetic and pharmacodynamic differences; intraspecies uncertainty (UF_H_) to account for variation in susceptibility across the human population, and the possibility that the available data may not be representative of individuals who are most susceptible to the effect; LOAEL-to-NOAEL uncertainty (UF_L_) to infer an exposure level where effects are not expected when a POD is based on a lowest-observed-adverse-effect level (LOAEL); subchronic-to-chronic uncertainty (UF_S_) to account for the uncertainty in using subchronic studies to make inferences about lifetime exposure, and to consider whether lifetime exposure would have effects at lower levels (e.g., for studies other than subchronic studies); and database uncertainty (UF_D_) to account for database deficiencies if an incomplete database raises concern that further studies might identify a more sensitive effect, organ system, or life stage. An explanation of the five possible areas of uncertainty and variability follows:

- An intraspecies uncertainty factor, UF_H_, of 3 (10^1/2^ = 3.16, rounded to 3) was applied to account for variability and uncertainty in pharmacodynamic susceptibility in extrapolating to subgroups of the human population most sensitive to the health hazards of Cr(VI) (U.S. EPA, 2002). In the case of Cr(VI), the PODs were derived from studies in inbred animal strains and are not considered sufficiently representative of the exposure and dose-response of the most susceptible human subpopulations (see Section 3.3.1). In certain cases, the pharmacokinetic component of this factor may be replaced when a PK model is available that incorporates the best available information on variability in pharmacokinetic disposition in the human population (including sensitive populations). In the case of Cr(VI), a Monte Carlo analysis using PBPK modeling (see Appendix Section C.1.5) was applied to account for pharmacokinetic variability. The POD was based on the lower 1% value, and therefore a value of 1 was applied for pharmacokinetic variability. A value of 3 was retained for pharmacodynamic variability. However, as noted in Section 4.1.5, not all uncertainties related to intraspecies variability can be quantified.
- An interspecies uncertainty factor, UF_A_, of 3 (10^1/2^ = 3.16, rounded to 3) was applied to all PODs to account for uncertainty in characterizing the pharmacokinetic and pharmacodynamic differences between rodents and humans. For all datasets used in this assessment, a PBPK model (along with BW^3/4^ scaling) was used to convert doses in rodents to equivalent doses in humans (see rationale in Section 4.1.2.1—Human Extrapolation). This reduces pharmacokinetic uncertainty in extrapolating from the rodents to humans,^74^ but does not account for interspecies differences due to pharmacodynamics. An UF_A_ of 3 was applied to account for this remaining pharmacodynamic and any residual pharmacokinetic uncertainty not accounted for by the PBPK model and BW^3/4^ scaling.
- A subchronic-to-chronic uncertainty factor, UF_s_, of 1 was applied to all endpoints (GI tract and liver effects) from the chronic 2-year (lifetime) study in rodents (NTP, 2008) where exposure occurred for 1 year or more. For example, ALT changes in rats measured at 1 year (12 months) were assigned an UF_S_ of 1. An UF_S_ of 1 was applied to the developmental endpoint from NTP (1997), because exposure occurred during the critical window. An UF_S_ of 1 was applied to decreased Hgb measured at subchronic timepoints from (NTP, 2007, 2008) because this effect is known to ameliorate over time, and therefore subchronic-derived PODs will be health-protective for chronic exposure. An UF_s_ of 3 was applied to ALT changes from the 90-day study in rodents (NTP, 2007), and ALT changes reported at 3 months during the chronic NTP (2008) study. An UF_S_ = 3 (rather than 10) was applied to 90-day data for ALT because data collected at multiple time points from NTP (2008) showed that these effects did not increase in severity between 90 days and 1 year. A value of 3 was retained to account for the possibility that longer exposure may induce these effects at a lower exposure (U.S. EPA, 2002), even if the effects themselves do not increase in severity. Also, there were no chronic ALT data for female rats, and females may be more susceptible (based on the observed chronic liver inflammation at 2 years). Similarly, an UF_s_ of 3 was applied to 90-day gastrointestinal tract endpoints in mice from Thompson et al.
- (2011) and NTP (2007) (n = 10 study), as well as the data for hyperplasia in the duodenum of female rats exposed for 90 days (Thompson et al., 2012b).
- A LOAEL-to-NOAEL uncertainty factor, UF_L_, of 1 was applied to PODs based on either a NOAEL or a BMDL. An UF_L_ of 10 (rather than 3) was applied to PODs based on the LOAEL of ALT changes in rats observed from the 90-day study (NTP, 2007), because the magnitude of change from control at the lowest dose was very high (180% for males and 585% for females). These measurements were somewhat volatile (for example, the changes were typically very large, and the magnitude of changes varied greatly between studies, even among the NTP studies in the same species and sex which were conducted under very similar conditions). As a result, the higher UF_L_ was applied. Similarly, an UF_L_ of 10 was applied to the LOAELs of hyperplasia in the female mouse duodenum and chronic liver inflammation in female rats from NTP (2008) because responses were high (>20% extra risk) at the lowest dose. Thus, an UF_L_ of 10 was applied to all PODs that were based on a LOAEL.
- A database uncertainty factor, UF_D_, value of 1 was applied for all endpoints. The toxicological database for oral exposure to Cr(VI) includes several occupational health studies, and subchronic and chronic toxicity studies in multiple laboratory species. The database also contains prenatal, multi-generational, and gestational oral studies in rodents.

Table 4-4 is a continuation of Table 4-3 and summarizes the application of UFs to each POD to derive a candidate value for each endpoint, preliminary to the derivation of the organ/system-specific reference values. These candidate values are considered individually in the selection of a representative oral reference value for a specific hazard and subsequent overall RfD for Cr(VI).

Table 4-4 Effects and corresponding derivation of candidate values

Endpoint and Reference | POD_HED_ (mg/kg-d) | POD Type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (mg/kg-d)
GI tract
Mouse (M) hyperplasia (2 yr) NTP (2008) | 0.0443 | BMDL_10%ER_ | 3 | 3 | 1 | 1 | 1 | 10 | 4.43 × 10^−3^
Mouse (F) hyperplasia (2 yr) NTP (2008) | 0.0911 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 9.11 × 10^−4^
Mouse (M) hyperplasia (90 d) (90 d) NTP (2007) | 0.0831 | BMDL_10%ER_ | 3 | 3 | 1 | 3 | 1 | 30 | 2.77 × 10^−3^
Mouse (F) hyperplasia (90 d) NTP (2007) | 0.267 | LOAEL | 3 | 3 | 10 | 3 | 1 | 300 | 8.90 × 10^−4^
Mouse (F) Crypt cell hyperplasia (90 d) Thompson et al. (2011) | 0.331 | NOAEL | 3 | 3 | 1 | 3 | 1 | 30 | 0.0110
Mouse (F) Villous cytoplasmic vacuolization (90 d) Thompson et al. (2011) | 0.154 | NOAEL | 3 | 3 | 1 | 3 | 1 | 30 | 5.13 × 10^−3^
Rat (F) hyperplasia (90 d) Thompson et al. (2012b) | 0.270 | NOAEL | 3 | 3 | 1 | 3 | 1 | 30 | 9.00 × 10^−3^
Liver
Rat (M) liver ALT (12 mo) NTP (2008) | 0.204 | BMDL_1RD_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0204
Rat (M) liver ALT (3 mo) NTP (2008) | 0.191 | NOAEL | 3 | 3 | 1 | 3 | 1 | 30 | 6.37 × 10^−3^
Rat (M) liver ALT (90 d) NTP (2007) | 0.203 | LOAEL | 3 | 3 | 10 | 3 | 1 | 300 | 6.77 × 10^−4^
Rat (F) liver ALT (90 d) NTP (2007) | 0.190 | LOAEL | 3 | 3 | 10 | 3 | 1 | 300 | 6.33 × 10^−4^
Rat (F) liver chronic inflammation (2 yr) NTP (2008) | 0.0669 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 6.69 × 10^−4^
Mouse (F) liver chronic inflammation (2 yr) NTP (2008) | 0.182 | BMDL_10%ER_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0182
Rat (F) liver fatty change (2 yr) NTP (2008) | 0.0669 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 6.69 × 10^−3^
Developmental
Mouse (F) Decreased F1 postnatal growth NTP (1997) | 0.700 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 0.0700
Hematological
Rat (M) Hgb (22 d) NTP (2008) | 0.126 | BMDL_1SD_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0126
Rat (M) Hgb (3 mo) NTP (2008) | 0.191 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 0.0191
Rat (M) Hgb (12 mo) NTP (2008) | 0.286 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 0.0286
Rat (M) Hgb (90 d) NTP (2007) | 0.227 | BMDL_1SD_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0227
Rat (M) Hgb (23 d) NTP (2007) | 0.259 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 2.59 × 10^−3^
Rat (F) Hgb (90 d) NTP (2007) | 0.312 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 0.0312
Rat (F) Hgb (23 d) NTP (2007) | 0.187 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 1.87 × 10^−3^

Note: An uncertainty factor of 3 indicates half an order of magnitude (10^1/2^ = 3.16, rounded to 3). For simplicity, 10^1/2^ is used when multiplying values of 3 together, and 3.0 is used when solely multiplying it by 1 or 10. An overview of uncertainty factor descriptions at the individual study level is available in Appendix D.7.

Figure 4-3 Derivation of organ/system-specific reference doses: Candidate values with corresponding POD and composite UF.

Table 4-5 distills the candidate values from Table 4-4 into a single value for each organ or system (organ/system-specific RfDs, or osRfDs). These organ or system-specific reference values may be useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site.

Each candidate value was evaluated with respect to multiple considerations, including strength of evidence, basis of the POD (i.e., BMD vs. NOAEL vs. LOAEL), and dose-response model uncertainties. The confidence rating of each osRfD is based on three factors: the level of confidence in the primary study, the health effect database associated with that reference value, and the quantification of the POD.

#### 4.1.3.1 GI Tract Toxicity

The osRfD for GI effects was based on the incidence of diffuse epithelial hyperplasia of the duodenum in female B6C3F1 mice reported in NTP (2008). Data in both males and females indicated that females may be more sensitive to this effect. Because the RfD is intended to protect the population as a whole including potentially susceptible subgroups (U.S. EPA, 2002), female data were selected for this osRfD. Candidate values of GI tract endpoints based on 90-day data were included for comparison; however, the chronic, 2-year exposure data were preferred to minimize uncertainties associated with the 90-day datasets (i.e., subchronic duration, smaller sample sizes, higher points of departure). The hyperplasia in the GI tract following chronic oral exposures is considered to be representative of the constellation of histopathological observations that together result in a change in tissue function that is considered an adverse noncancer effect. An osRfD of 9 × 10^−4^ mg/kg-day (rounded from 9.11 × 10^−4^) was derived. There is medium-high confidence in this osRfD. It is based on chronic 2-year data from a high confidence study with a supporting evidence base of subchronic and mechanistic studies, and a strong dose-response for GI hyperplasia was exhibited in both male and female mice. However, the data in female mice were not amenable to BMD modeling, thus the LOAEL was used as the POD (see Section 4.1.2.2).

#### 4.1.3.2 Hepatic Toxicity

The osRfD for hepatic effects was based on the lowest candidate toxicity value from the chronic data: chronic inflammation in female F344 rats reported in NTP (2008). As with GI effects, chronic data were preferred. Subchronic data of ALT are consistently supportive in showing liver injury at nearly all dose groups; however, those data were highly variable, and in some cases exhibited nonmonotonic dose-response relationships. Histological changes were primarily observed in female rats and were less severe in male rats and mice. Therefore, female rats may be the most sensitive group. Chronic hepatic inflammation can lead to fibrosis (Koyama and Brenner, 2017); however, more severe manifestations of toxicity (e.g., necrosis, fibrosis) were not observed in the NTP (2008) 2-year study. Therefore, this candidate value may be predictive of subsequent, more severe perturbations and is believed to be protective of the other endpoints evaluated using chronic data (increased fatty changes and increased ALT). An osRfD of 7 × 10^−4^ mg/kg-day (rounded from 6.69 × 10^−4^) was derived. There is medium-high confidence in this osRfD. It is based on a high confidence chronic study in rats and there are other subchronic data and mechanistic evidence to support the liver endpoints. However, overall confidence in this value is somewhat reduced due to the minimal severity of the chronic inflammation, and because the data for this endpoint were not amenable to BMD modeling, the LOAEL was used as the POD (see Section 4.1.2.3).

#### 4.1.3.3 Developmental Toxicity

The osRfD for developmental toxicity was based on the only candidate value: decreased F1 offspring postnatal growth from the continuous breeding study in BALBC mice (NTP, 1997). The osRfD was 0.07 mg/kg-day. There is low confidence in this osRfD. While it is based on a high confidence continuous breeding study and similar effects on decreased offspring growth observed in multiple other studies (see Section 3.2.9, click the HAWC link for study evaluation details), this effect only occurred in high dose groups where other toxicological effects (as indicated by the lower points of departure in this section) may be occurring. For example, female mice in the F0 generation (dams) were exposed to 11.6, 24.4, 50.6 mg/kg-day Cr(VI) (NTP, 1997). The decreased F1 offspring growth effect was observed at maternal dose of 24.4 mg/kg-day, which is a relatively high dose (NTP (2007) observed high incidence of stomach ulcers in rats at approximately 20 mg/kg-day). Other studies in the database observing similar effects were lower confidence and used higher (or unknown) doses. A lower osRfD confidence was assigned due to: (1) a weak health effects database for this endpoint (most studies were rated low confidence), and (2) the possibility that other unknown toxicities could be affecting the animals at the high dose. Thus, there was lowered confidence due to the database of studies examining this endpoint, and lowered confidence in quantification of the POD.

#### 4.1.3.4 Hematological Toxicity

The osRfD for hematological toxicity was based on decreased Hgb in male F344 rats at 22 days reported in NTP (2008). This effect was observed to have the highest magnitude at short time periods, and other short-term data (such as 23-day data from NTP (2007)) were not as applicable for low-dose extrapolation due to the higher dose ranges used. An osRfD of 0.01 mg/kg-day (rounded from 0.0126 mg/kg-day) was derived. There is medium confidence in this osRfD. It is based on a high confidence (https://hawc.epa.gov/summary/visual/assessment/499/Cr6-animal-hematological-literature-summary/) study in rats that measured data at multiple time points. In addition, there are other subchronic datasets, mechanistic evidence, and multiple hematological markers (e.g., MCV, MCH, MCHC, Hct) that support this endpoint. However, overall confidence in this osRfD is somewhat diminished due to the transient nature of the observed hematological effects (see Section 3.2.5).

Table 4-5 Organ/system-specific RfDs and proposed overall RfD for Cr(VI)

Effect | Basis | osRfD (mg/kg-d) | Exposure description | Confidence
GI tract toxicity | Diffuse epithelial hyperplasia in small intestine (female mice) | 9 × 10^−4^ | Chronic | Medium-High
Hepatic toxicity | Chronic inflammation (female rats) | 7 × 10^−4^ | Chronic | Medium-High
Developmental toxicity | Decreased F1 offspring postnatal growth (mice) | 0.07 | Continuous breeding | Low
Hematological toxicity | Decreased Hgb (male rats) | 0.01 | Subchronic | Medium
Overall RfD | GI tract effects | 9 × 10^−4^ | Chronic | Medium-High

### 4.1.4 Selection of the Overall Reference Dose

Choice of the overall RfD involved consideration of both the level of certainty in the estimated organ/system-specific values, as well as the level of confidence in the observed effect(s). An overall confidence level was assigned to the RfD to reflect an interpretation regarding confidence in the collection of studies used to determine the hazard(s) and derive the RfD, the RfD calculation itself, as well as the overall completeness of the database on the potential health effects of Cr(VI) exposure.

To estimate an exposure level below which noncancer effects from lifetime oral Cr(VI) exposure are not expected to occur, the osRfD for GI effects, 9 × 10^−4^ mg/kg-day, is selected as the overall RfD for Cr(VI). This was a medium-high confidence value derived from chronic exposure data. The overall RfD is derived to be protective of all types of noncancer effects for lifetime exposure and is intended to protect the population as a whole including potentially susceptible subgroups (U.S. EPA, 2002). While the osRfD for liver was slightly lower, due to the minimal severity of the chronic liver inflammation observed in female rats in the two-year bioassay (characterized by NTP (2008) as a “chronic inflammatory process of minimal severity” and “consistent with changes that are considered to be background or spontaneous lesions commonly observed in aged rats”), the uncertainty in the POD is considered to be larger for the hepatic osRfD, as more severe manifestations of toxicity (e.g., necrosis, fibrosis) were not observed in the selected study. Alternatively, for GI effects, more severe manifestations of toxicity (e.g., degenerative changes) were observed in the selected study, thus reducing this concern and better supporting the selection of the less severe changes as predictive of subsequent, more severe perturbations. Therefore, the histological lesion of diffuse epithelial hyperplasia in the GI was preferred as the basis of the overall RfD (see Figure 4-3).

This value (9 × 10^−4^ mg/kg-day) should be applied in general population risk assessments. However, decisions concerning averaging exposures over time for comparison with the RfD should consider the types of toxicological effects and specific life stages of concern. For example, fluctuations in exposure levels that result in elevated exposures during various life stages could potentially lead to an appreciable risk, even if average levels over the full exposure duration were less than or equal to the RfD.

### 4.1.5 Uncertainties in the Derivation of Reference Dose

The RfD was derived based on GI effects (diffuse epithelial hyperplasia in the duodenum) of female mice exposed to Cr(VI) in drinking water for 2 years (NTP, 2008). Some of the uncertainty considerations related to the RfD derivation are outlined below and in Section 3.3.

#### 4.1.5.1 Site Concordance and Human Relevance

The GI tract reference value was based on an effect observed in the small intestine of mice; however, it is possible that the effect may be exhibited in different sections of the alimentary tract in the human (specifically, the oral cavity, esophagus, and stomach). Estimated Cr(VI) exposure to the stomach epithelium may be similar to exposure to the small intestine epithelium, since both would be strong functions of gastric pH, Cr(VI) concentration and reduction rate. There are differences in morphologies between the small intestine and stomach that could potentially impact the tissue susceptibility. Effects in the rodent stomach only occurred at the high doses of the 90-day NTP (2007) study. Rodents exposed to Cr(VI) during the 2-year NTP (2008) study did not exhibit effects in the stomach.

Exposure to the oral cavity and esophagus occurs prior to Cr(VI) reduction in the stomach. However, no noncancer effects were observed in these tissues during the NTP (2008) or NTP (2007) bioassays (aside from mild salivary gland atrophy in rats during the 2-year study).

#### 4.1.5.2 Susceptible Populations

A significant fraction of the human population may be highly susceptible to Cr(VI)-induced effects in the GI tract due to high stomach pH. Individuals with hypochlorhydria (low stomach acid) have consistently high stomach pH that may exceed 8 (Feldman and Barnett, 1991). Less than 1% of the adult population may exhibit hypochlorhydria, whereas 10%–20% of the elderly population (aged 65 and up) may exhibit this condition (Russell et al., 1993). For individuals without this medical condition, there is still high variability (Feldman and Barnett (1991) estimated that 5% of men may exhibit basal pH exceeding 5, and 5% of women may exhibit basal pH exceeding 6.8). Gut microbiota and gastric juice chemistry in individuals with high gastric pH may differ from those in the general population. It is not known how effective Cr(VI) can reduce to Cr(III) in this type of gastric environment. Data by Kirman et al. (2016), which included some groups with high stomach pH, were highly variable.

Individuals taking medication to treat gastroesophageal reflux disease (GERD), including calcium carbonate-based acid reducers and proton pump inhibitors, have an elevated stomach pH during treatment. This is known to be a significant fraction of the population since up to 20% of the population may be afflicted by GERD, and the gastric pH for these individuals may be above 4 throughout the day during successful treatment (Lin and Triadafilopoulos, 2015; GBD 2017, 2020; Delshad et al., 2020; Burdsall et al., 2013; Atanassoffet al., 1995). A sensitivity analysis was performed on the human model (see Appendix C.1.5), assuming a baseline stomach pH = 4 (as opposed to 1.3). It was found that for internal PODs above 0.001 mg/kg-day (which apply to all the PODs), the current Monte Carlo approach (taking the lower 1% of 20,000 simulations of the standard population with baseline stomach pH = 1.3) was protective for the population with baseline pH = 4. For populations with baseline pH higher than 4, candidate values derived using the pharmacokinetic approach would not be health protective. Appendix D.3 contains candidate values calculated by default approaches without adjustment for gastric reduction, which may be health-protective at low doses for the pH > 4 population (since those results implicitly assume gastric pH and reduction capacity in rodents and humans are equivalent).

Uncertainties related to extremely high gastric pH, as well as other conditions that could lead to pharmacokinetic susceptibility (H. pylori infection, gastric bypass, gastrectomy) cannot be accounted for quantitatively. High interindividual variation was observed in ex vivo data by Kirman et al. (2016), both in health individuals with high stomach pH and individuals taking proton pump inhibitors. Additionally, no data are available studying Cr(VI) reduction in the gastric environments of children, toddlers, or infants. As a result, PBPK modeling was not performed for these groups, and there may be some residual pharmacokinetic uncertainty not accounted for by the UF_H_.

#### 4.1.5.3 Rodent Gastric Modeling Uncertainties

Stomach reduction in the mouse may be impacted by a number of factors. Higher reduction efficiency may occur during the ingestion of a solid meal, since gastric emptying is delayed, and pH is decreased (for the mouse, glandular stomach pH is decreased by the fasted state, while the opposite is true for humans). However, this effect may be counteracted by kinetics in the forestomach, which humans do not have. The forestomach may not follow the same fed/fasted pattern as the glandular stomach (Ward and Coates, 1987).

The rodent glandular stomach actively secretes digestive enzymes shortly before, during, and after a solid meal. The precise dynamics of gastric changes are uncertain, and the “well-mixed” PBPK model assumption may not be accurate due to ongoing food consumption. In addition, the rodent forestomach contents may have an elevated pH relative to the glandular stomach (Kunstyr et al., 1976; Kohl et al., 2013; Browning et al., 1983), and ingested drinking water passes through both of these stomach regions.

There are also uncertainties related to the pH-kinetic relationship. The dose-response analysis for this assessment applied rodent pH of greater than 4.0, setting pH to values at which the rodent ex vivo reduction experiments were performed. Prior to dilution with water, Proctor et al. (2012) estimated the rodent stomach pH to be approximately 4, but it was increased to approximately 4.5 after dilution with water for the experiments. The precise relationship between pH and reduction kinetics in the rodent at lower pH is uncertain, and therefore it was desirable to perform simulations assuming rodent pH of 4.0 or higher. If the true rodent stomach pH is lower, or if the reduction kinetics are faster than estimated by the current model, this would ultimately lead to a decreased RfD. On the other hand, the model already estimates a low percentage of Cr(VI) escaping the rodent stomach (5%–10%). If the true percentage was lower than this, it would mean that a negligible amount of Cr(VI) enters the mouse small intestine following ingestion. It has been confirmed by multiple pharmacokinetic studies that Cr(VI) is absorbed systemically in rodents following exposure via drinking water. Data by Kirman et al. (2012) show chromium concentrations in the duodenum increasing with a linear or supralinear relationship with respect to dose in mice exposed to Cr(VI) in drinking water for 90 days. Data by NTP (2008) show elevated tissue chromium for all chronically exposed groups. Therefore, assuming that in vivo rodent gastric reduction occurs very effectively (i.e., 99% reduction) would not be consistent with the available pharmacokinetic data.

#### 4.1.5.4 Human Gastric Modeling Uncertainties

As with the rodent gastric system, there are uncertainties in modeling the human stomach. There exist complex gastric and intestinal kinetic models, and many of the parameters are highly variable (Yu et al., 2017; Talattof and Amidon, 2018; Paixão et al., 2018; Mudie et al., 2010; ICRP, 2006; Hens et al., 2014). While the PBPK model in this assessment adopts some parameters and concepts from literature, and incorporates Monte Carlo analysis, it may not account for all uncertainty and variability. Ex vivo data for Cr(VI) reduction in gastric juices show high interindividual variability Kirman et al. (2016); De Flora et al. (2016). Interindividual variability in gastric contents and microbiota likely introduces variation in Cr(VI) reduction. Variability in reduction kinetic parameters (with the exception of the reducing capacity parameter) was not incorporated into the model. Furthermore, there are no data for Cr(VI) reduction in the gastric acid of infants and toddlers, and there would be significant uncertainties in applying the adult-based PBPK model to infant or child physiology.

Additional uncertainties relevant to active transport and diffusion are discussed in Section 3.1.2.2.

#### 4.1.5.5 Uncertainty in Systemic Pharmacokinetics

The current approach uses a PBPK model of the stomach lumen to adjust the average daily oral Cr(VI) dose to account for detoxification in the stomach compartment. It does not explicitly model systemic whole-body pharmacokinetics. While whole-body PBPK models are available for Cr(VI), the uncertainties related to the systemic pharmacokinetics in rodents and humans are high, especially at low doses. However, most endpoints observed following oral ingestion were in or near the GI tract, and therefore may not require an accounting of systemic chromium. Cr(VI) which enters the intestinal lumen may expose the systems in which effects were observed (the small intestine, and the liver by first-pass effect) prior to distribution to systemic circulation. Reduction of Cr(VI) in the blood and other tissues is rapid, and this assessment neglects the impact that recirculating Cr(VI) may have on the liver and small intestine. It is health-protective to assume that any unreduced Cr(VI) emptying into the human small intestine is absorbed.

For systemic effects, there is some residual pharmacokinetic uncertainty. The modeling does not take into account how much Cr(VI) may remain in the GI epithelium (or be reduced by the G.I. tissues, liver, and blood). This loss of Cr(VI) available to absorb into systemic tissues is neglected in both animals and humans.

#### 4.1.5.6 Uncertainty in Dose-response Modeling

For the two osRfDs (diffuse epithelial hyperplasia in female mice, and chronic liver inflammation in female rats from NTP (2008)), there was uncertainty related to the dose-response modeling. Thus, a NOAEL/LOAEL approach was used.

As noted in Section 4.1.2.2, diffuse epithelial hyperplasia was not amenable to BMD modeling for female mice because there was too much uncertainty in estimating the BMDL. Estimates of the epithelial hyperplasia RfD from female mice using BMD modeling (without dropping doses) span from 7.95 × 10^−5^ mg/kg-day to 2.04 × 10^−3^ mg/kg-day (see Appendix D.1.1). The GI tract osRfD (derived by a LOAEL, which resulted in a higher uncertainty factor) falls within this span and differs by approximately 15% from both the mean and median value of the three adequately fit models (1.06 × 10^−3^ mg/kg-day). If dropping the two highest doses (as was done by (ATSDR, 2012)) and performing BMD modeling, the resulting RfD would be 2.6 × 10^−3^ mg/kg-day (and rounded to 3 × 10^−3^ mg/kg-day). EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012b) states dropping dose groups should only be done when an adequate model fit cannot be achieved. This situation did not apply to female mouse hyperplasia, because multiple adequate fits were achieved when including all dose groups, but there was too much uncertainty in the BMD estimate to use these model results for determining the POD.

Similarly, chronic liver inflammation in female rats from NTP (2008) was not amenable to BMD modeling. Estimates of the candidate values for this endpoint span from 1.00 × 10^−4^ to 4.02 × 10^−3^ (see Appendix D.1.1). The liver osRfD (derived by a LOAEL, which resulted in a higher uncertainty factor) falls within this span and is about 2× lower than the mean and median values of the three adequately fit models (mean: 1.80 × 10^−3^ mg/kg-day, median: 1.28 × 10^−3^ mg/kg-day).

#### 4.1.5.7 Potential Low-dose Nonlinearities in Pharmacokinetics

In the low-dose range, humans are more efficient at reducing Cr(VI) in the gastric compartment than rodents. As a result, estimation of the human equivalent dose (HED) can be affected by the dose level at which the extrapolation is performed. An alternative uncertainty factor approach applies some uncertainty factors that represent uncertainties on the internal rodent dose (specifically UF_L_ and UF_A_) to the rodent internal dose prior to calculation of the HED (see Table 4-6). The remaining uncertainty factors are then applied after HED calculation to estimate the candidate RfDs (see Table 4-7). The EPA has previously applied uncertainty factors to internal doses identified in rodent studies in its IRIS Toxicological Review of Methanol (Noncancer) (U.S. EPA, 2013) (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=260110), though in that case the objective was to avoid extrapolation of the human PBPK model outside its range of calibration rather than addressing nonlinearity. For this approach, HED calculations are performed at a lower dose region, where humans are even more efficient than rodents at reducing Cr(VI) in the stomach than at higher doses, i.e., where the ratio of internal to ingested dose ([internal dose]/HED) is lower because of the greater reduction efficiency, hence the reciprocal of this relationship, HED/[internal dose], is higher. This potential nonlinearity was evaluated at the lowest PODs, for which UF_A_ × UF_L_ (30) was also applied. The data were still not amenable to BMD modeling, even after converting to internal dose.

Table 4-6 Summary of derivation of points of departure following oral exposure using alternative uncertainty factor process

Species/Sex | LOAEL mg/kg-d | Internal dose^a^ mg/kg-d | TWA BW (kg) | BW^3/4^ adjust^b^ | UF_A_, UF_L_ | Internal dose POD | POD_HED_ (mg/kg-d)^c^
Diffuse epithelial hyperplasia of the duodenum at 2 yr ( NTP, 2008 )
Mice/F | 0.302 | 0.0463 | 0.05 | 7.32 × 10^−3^ | 3, 10 | 2.44 × 10^−4^ | 4.13 × 10^−3^
Chronic liver inflammation at 2 yr ( NTP, 2008 )
Rat/F | 0.248 | 0.0195 | 0.260 | 4.66 × 10^−3^ | 3, 10 | 1.55 × 10^−4^ | 2.64 × 10^−3^

a Dose escaping stomach reduction in rodent (mg/kg-d) estimated by PBPK modeling.

b BW^3/4^ scaling adjustment: mg/kg-d multiplied by (BW_A_/80)^1/4^. Animal BW set to study/sex-specific time weighted average values for hybrid PBPK modeling/BW^3/4^ scaling approach to maintain consistency with bioassay PBPK simulation.

c POD_HED_ in mg/kg-d Cr(VI) oral dose ingested by humans (lower 1% value of 20,000 Monte Carlo PBPK simulations needed to achieve the internal dose POD). See Appendix C.1.5 for details.

Table 4-7 Effects and corresponding derivation of candidate values using alternative uncertainty factor process

Endpoint and reference | POD_HED_ (mg/kg-d) | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF^a^ | Alternate candidate RfD value (mg/kg-d)^b^
Digestive tract tissues
Mouse (F) hyperplasia NTP (2008) | 4.13 × 10^−3^ | LOAEL | [3] | 3 | [10] | 1 | 1 | 100 | 1.38 × 10^−3^ (1 × 10^−3^)
Liver
Rat (F) liver chronic inflammation (2 yr) NTP (2008) | 2.64 × 10^−3^ | LOAEL | [3] | 3 | [1] | 1 | 1 | 10 | 8.80 × 10^−4^ (9 × 10^−4^)

a UF_A_ and UF_L_ have been applied to the internal rodent dose prior to calculation of the POD_HED_, while UF_H_ was applied after calculation of the POD_HED_. The listed composite UF is the product of all the uncertainty factors that have been applied in all steps.

b Value in parenthesis is after rounding to one significant figure.

Because rodent-to-human extrapolation already occurred at low doses, there was only a slight increase in the candidate RfDs for liver and GI tract toxicity if human extrapolation were performed at a lower dose region. The GI candidate RfD would increase by 11%, from 9 × 10^−4^ (see Table 4-5) to 1 × 10^−3^ mg/kg-day, and the liver RfD would increase by 29%, from 7 × 10^−4^ (see Table 4-5) to 9 × 10^−4^ (with discrepancies due to rounding to the nearest value). Because the RfD is defined as an estimate with uncertainty spanning perhaps an order of magnitude, these are not considered significant changes and provide insufficient justification to adopt the alternative process.

### 4.1.6 Confidence Statement

An overall confidence level of High, Medium, or Low was assigned to reflect the level of confidence in the study(ies) and hazard(s) used to derive the RfD, the overall database, and the RfD itself, as described in EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry §4.3.9.2 (U.S. EPA, 1994). The confidence in the overall chronic RfD is Medium-High. The RfD is based on a high confidence chronic 2-year drinking water study by NTP (2008) which exposed rats and mice of both sexes to Cr(VI) as sodium dichromate dihydrate at drinking water concentrations from 5 mg/L to 180 mg/L (approximately 0.2 mg/kg-day to 10 mg/kg-day). Multiple high confidence subchronic studies also support these data (click the HAWC link for study evaluation details), and mechanistic studies support oxidative stress as a mechanism of Cr(VI) toxicity in a variety of tissues, including the GI tract. Overall confidence in this osRfD is somewhat reduced because the data for this endpoint are not amenable to BMD modeling, resulting in the reliance on a LOAEL as the POD, although the final result is supported by BMD modeling results for hyperplasia in the duodenum of male mice from the same study and is within the range of adequately fit models that could not be utilized (see above in Section 4.1.5.6). While the human database for Cr(VI)-induced GI toxicity was indeterminate, this did not warrant changing the overall confidence from medium-high.

### 4.1.7 Previous IRIS Assessment: Oral Reference Dose

The previous RfD assessment for Cr(VI) was completed in September 1998 (U.S. EPA, 1998c). The previous RfD was based on a NOAEL identified from a 1-year drinking water study in rats in which animals were exposed to Cr(VI) (MacKenzie et al., 1958).^75^ MacKenzie et al. (1958) monitored body weight, gross external conditions, histopathology, and blood chemistry and did not observe any effects at any level of treatment. A NOAEL of 2.5 mg/kg-day was identified. A composite uncertainty factor of 300 (10 for interspecies extrapolation, 10 for intraspecies extrapolation, and 3 for subchronic-to-chronic extrapolation) and a modifying factor of 3 (to account for concerns raised by the epidemiology study of Zhang and Li (1987a)) were applied to this POD to yield an oral RfD of 3 × 10^−3^ mg/kg-day. The value of the RfD in the current assessment (9 × 10^−4^ mg/kg-day) is within approximately threefold of this value.

## 4.2 INHALATION REFERENCE CONCENTRATION FOR EFFECTS OTHER THAN CANCER

The reference concentration (RfC, expressed in units of mg/m^3^) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a NOAEL, LOAEL, or the 95% lower bound on the benchmark concentration (BMCL), with uncertainty factors generally applied to reflect limitations of the data used. As noted in Section 3.3.2, derivation of the RfC was limited to effects in the respiratory tract.

Upper respiratory toxicity in the form of nasal effects in humans has been determined previously (see Protocol Section 3.1.2, Appendix A), and a set of human studies were evaluated for data that may inform the quantitative dose-response analysis (this will be discussed in Section 4.2.1). Data suitable for RfC derivation of upper respiratory effects were only available from human studies (and these were limited to effects in the nasal airways). Data from animals of effects in the upper respiratory tract (such as reported nosebleeds and other qualitative effect descriptions) were not considered due to the availability of quantitative dose-response data in humans.

On the basis of findings from inhalation studies in experimental animals and occupational studies in humans, evidence indicates that Cr(VI) is likely to cause lower respiratory toxicity in humans (see Section 3.2.1). Data suitable for RfC derivation of lower respiratory effects were only available from animal studies. All human studies of these effects were low confidence and only provided information on associations (and did not provide dose-response data).

### 4.2.1 Identification of Studies for Dose-Response Analysis of Selected Effects

#### 4.2.1.1 Upper Respiratory Tract Effects

Effects in the nasal cavity of humans are well-established hazards of inhaled Cr(VI) exposure; therefore, this review focused on data that may improve the quantitative dose-response analysis conducted in EPA’s 1998 IRIS assessment (see Protocol Section 3.2, Appendix A).^76^ Quantitative animal data for effects in the upper respiratory tract were not available. Qualitative findings in rodents such as obstructive respiratory dyspnea (Glaser et al., 1990), or “peculiar sound during respiration” and periodic nose bleeds (Kim et al., 2004) were not considered for dose-response assessment due to the availability of human data. No other effects in the upper respiratory tract outside of the nasal cavity were identified during hazard identification (see Section 3.2.1).

The epidemiological database for inhalation of Cr(VI) mainly consists of observational studies of workers exposed in occupational settings. Human studies were considered suitable for dose-response analysis and toxicity value derivation if they met the criteria listed below. Furthermore, preference was given to studies with medium or high overall confidence ratings based on study evaluation and to studies with larger sample sizes and exposures in the lower range of human exposures, as these are most likely to represent the relationship between inhalation exposure to Cr(VI) and adverse effects in the general population.

The following considerations were made during evaluation of studies for derivation of inhalation toxicity values from human data:

- The study population must be exposed to Cr(VI) (as opposed to Cr(III)) based on air measurements or job history and industry
- Quantitative estimates relating exposure (or dose) to the core outcomes considered
- Concentration of Cr(VI) in air must be measured at the study site
- Quality of measurements will depend on: type of sampling (personal, stationary, or both); frequency of sampling; sampling duration; number of samplers; sampling methods
- Exposure to Cr(VI) for individuals or groups of individuals must be estimated with reasonable accuracy and precision in units of air concentration
- If exposure is categorical, it must have corresponding air concentration estimates for each category
- Exposure is not solely quantified in units of concentration in a biological sample such as urine or blood

The core outcomes for nasal effects in humans considered for evaluation of dose response included the following clinical outcomes diagnosed by a trained examiner (e.g., physician, otolaryngologist, or trained researcher): atrophy of the nasal mucosa, ulceration of the nasal mucosa or septum, perforation of the septum, and bleeding nasal septum. The development of these outcomes has been established to result from inhalation exposure to Cr(VI) due to the elevated prevalence of nasal septum perforation among workers exposed to Cr(VI). For example, a study of workers in chromate-producing plants in the early 1950s conducted by the U.S. Public Health Service reported a prevalence of nasal septum perforation in 57% of 897 workers in six chromate producing plants (PHS, 1953). In a seventh plant in Ohio, nasal septum perforation was reported in 63% of 97 chromate production workers (Mancuso, 1951). In fact, perforation of the septum has been known as “chrome hole” since the early days of chromium-related industries, including chromate production and electroplating (Pye, 1885; Bloomfield and Blum, 1928). The consistency across these two occupational settings shows that exposure to other chemicals is not responsible, as the co-exposures in an electroplating factory are different from the co-exposures in a chromate factory. Furthermore, the presence of nasal pathologies considered here are occasionally used as supplemental information to confirm exposure to chromium in studies of non-nasal outcomes (Machle and Gregorius, 1948; Gibb et al., 2015; Ciminera et al., 2016). While nonindustrial causes of nasal perforation include piercing, disease, surgical trauma, and illicit drug use, the prevalence of nasal perforation in the general population is only 0.5%‒3.1% (Lanier et al., 2007; Downs and Sauder, 2023), making this outcome to Cr(VI) exposure in occupational settings appropriate for the estimation of the dose-response relationship for noncancer effects in humans.

Title and abstract screening was performed on human health studies obtained from the literature searches described in Sections 1.2 and 2.1, and backward searching was performed using reference lists from included studies and the 1998 Cr(VI) assessment (U.S. EPA, 1998c). There were over 20 peer-reviewed studies of nasal effects that contained information related to endpoints in the nasal cavity, but these did not meet all criteria for dose-response analysis outlined above and were therefore not evaluated. There were also five non-peer-reviewed reports examining effects in the nasal cavity available from the National Institute for Occupational Safety and Health (NIOSH): Ceballos et al. (2017), Zey and Lucas (1985), Lucas (1976), Lucas and Kramkowski (1975), Cohen and Kramkowski (1973) and Almaguer and Kramkowski (1983).^77^ Many of these studies did not have multiple exposure groups (either a referent or low/high concentration groups). Exposure and health effect data from these studies were only available for short time periods, and data were only collected after health effects were reported for the purpose of evaluating plant industrial hygiene practices (potentially leading to bias). As a result, most of these were excluded for dose-response consideration. Only data from Cohen and Kramkowski (1973) and its related peer-reviewed study (Cohen et al., 1974) were considered because this study contained a referent group. All studies excluded based on criteria above are listed at the bottom of Table 4-8, and a detailed rationale for why each of these were not considered is provided in Appendix D.4 Table D-16.

Four peer-reviewed studies (some of which were associated with additional related studies containing exposure or study design information) initially met the criteria to be considered for toxicity value derivation and underwent formal study evaluation using HAWC. These were Gibb et al. (2000a), Lindberg and Hedenstierna (1983), Cohen et al. (1974), and Hanslian et al. (1967). All were conducted in occupational settings and the study populations were workers in either the chromate production or chrome electroplating industries. One study of 2,307 chromate production workers Gibb et al. (2000a), though retrospective in design, utilized company records of air concentration data, individual job and task data, and data from regular medical examinations to construct a dataset that included individual exposure estimates for each worker as well as the time from baseline exposure to the incident event of the health outcome (see Table 4-28 in Section 4.4.5). The other three studies (Lindberg and Hedenstierna, 1983; Hanslian et al., 1967; Cohen et al., 1974) were cross-sectional in design and were conducted in smaller study populations composed of chrome electroplating workers. The populations of all four studies were adults, and the largest cohort (Gibb et al., 2000a) only had male workers.

Three studies were classified as medium confidence (Lindberg and Hedenstierna, 1983; Gibb et al., 2000a; Cohen et al., 1974), and one study was low confidence (Hanslian et al., 1967). Because of the availability of medium confidence studies, data from Hanslian et al. (1967) were no longer considered for dose-response. In addition to the usual factors considered during study evaluation, diagnosis of nasal outcomes after physical examination of the nasal cavity by a trained examiner was considered when determining confidence ratings for nasal effects studies. Additional study details, including the reported endpoint data, are provided in Table 4-9.

Table 4-8 Evaluation of epidemiology studies on Cr(VI) and nasal effects.

Click to see interactive data graphic for rating rationales. (https://hawcprd.epa.gov/summary/visual/100500655/)

Included | Reference | Study description | Study evaluation
Included | Reference | Study description | Exposure | Outcome | Selection | Confounding | Analysis | Sensitivity | Sel. reporting | Overall confidence
Included | Gibb et al. (2000a) related: Gibb et al. (2015) Hayes et al. (1979); Braver et al. (1985) | Occupational longitudinal study. Male workers in a chromate production plant in Baltimore, MD (n = 2,307). | A | A | A | A | A | G | A | MED
Included | Lindberg and Hedenstierna (1983) | Cross-sectional study. Male and female employees in chrome-plating industry (n = 104). Office employees (n = 19) as reference group. | A | A | A | A | A | A | A | MED
Included | Cohen et al. (1974) Related: Cohen and Kramkowski (1973) | Cross-sectional study. White male and female electroplating workers in nickel-chrome department (n = 37). Randomly chosen workers employed in other areas of the plant not significantly exposed to chromic acid as reference group (n = 15). | A | G | A | A | A | A | A | MED
Excluded | Hanslian et al. (1967) | Cross-sectional study. Male and female chrome-plating workers (n = 77). 53 working directly with baths, 23 working directly with chromium. No reference group. | D | A | D | A | A | A | A | LOW
Not suitable ^a^ | Almaguer and Kramkowski (1983);Armienta-Hernández and Rodríguez-Castillo (1995); Bloomfield and Blum (1928); Ceballos et al. (2017); (2019); Dornan (1981); Elhosary et al. (2014); Fagliano et al. (1997); Gomes (1972); Horiguchi et al. (1990); Huvinen et al. (2002a); Kleinfeld and Rosso (1965); Kitamura et al. (2003); Korallus et al. (1982); Lee and Goh (1988); Lin et al. (1994); Lucas and Kramkowski (1975); (1976); Machle and Gregorius (1948); Mancuso (1951); PHS (1953); Royle (1975); Singhal et al. (2015); Vosoughifar (2016); Vigliani and Zurlo (1955); Sorahan et al. (1987), Wang et al. (1994); Yuan et al. (2016), Zey and Lucas (1985)

G = good; A = adequate; P = poor.

a Studies that may have contained data for effects in the nasal cavity but were determined not to meet PECO within the scope of derivation of nasal toxicity values or were not suitable for dose-response analysis for other reasons. Rationale for excluding individual studies is available in Appendix D4, Table D-16.

Table 4-9 Dose-response data for effects in the nasal cavity of humans (medium confidence studies)

Study | Exposure | Conf | Result format | Effects
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | Ulceration | | | Atrophy | | | Perforation only*
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | [underlined: 8-hr mean air μg Cr(VI)/m^3^] | | | [underlined: 8-hr mean air μg Cr(VI)/m^3^] | | | [underlined: 8-hr mean air μg Cr(VI)/m^3^]
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | Group | n | cases (%) | Group | n | cases | Group | n | cases(%)
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | ≤1.9 | 19 | 0 | ≤1.9 | 19 | 4 (21) | ≤1.9 | 19 | 0
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | 2–20 | 24 | 8 (33) | 2–20 | 24 | 8 (33) | 2–20 | 24 | 3 (13)
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | [underlined: Highest air μg Cr(VI)/m^3^] | | | [underlined: Highest air μg Cr(VI)/m^3^] | | | [underlined: Highest air μg Cr(VI)/m^3^]
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | Group | n | cases | Group | n | cases | Group | n | cases
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | 0.2–1.2 | 10 | 0 | 0.2–1.2 | 10 | 1 (10) | 0.2–1.2 | 10 | 0
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | 2.5–11 | 12 | 0 | 2.5–11 | 12 | 8 (67) | 2.5–11 | 12 | 0
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | 20–46 | 14 | 7 (50) | 20–46 | 14 | 0 | 20–46 | 14 | 3 (21)
Lindberg and Hedenstierna (1983) | Chrome plating | MED | Number of cases | | | | | | | *2 w/ulceration also had perforation (total w/ perforation = 5)
Gibb et al. (2000a) | Chromate production | MED | Cumulative incidence (%) (n = 2,307), onset time, and relative risk (ulceration only) | Ulcerated nasal septum; Effect: 62.9%; Mean (median) exposure: 0.054 (0.020) mg CrO_3_/m^3^ or 28 (10) μg Cr(VI)/m^3^; Mean (median) time on job (d) from date first hired to date of first diagnosis: 86 (22) | | | Perforated nasal septum; Effect: 17.3%; Mean (median) exposure: 0.063 (0.021) mg CrO_3_/m^3^ or 33 (11) μg Cr(VI)/m^3^; Mean (median) time on job (d) from date first hired to date of first diagnosis: 313 (172) | | | Ulcerated septum relative risk; Adjusted relative risk for a 0.1 mg CrO_3_/m^3^ increase (in ambient air) = 1.2 (by Cox proportional hazards model adjusted for calendar yr at hire and age at hire, p = 0.0001).
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | Nasal ulceration parameter cases, number (%) | | | | | | nonexposed (n=15) | | exposed (n=37)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | nasal mucosa (grade 0) | | | | | | 14 (93) | | 2 (5)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | shallow erosion of septal mucosa (grade 1) | | | | | | 0 | | 8 (22)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | ulceration and crusting of septal mucosa (grade 2) | | | | | | 0 | | 12 (32)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | avascular, scarified areas of septal mucosa w/o erosion or ulceration (grade 3) | | | | | | 0 | | 11 (30)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | perforation of septal mucosa (grade 4) | | | | | | 1 (7) | | 4 (11)
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | Exposed group area breathing zone: mean = 2.9 (ND–9.1) μg Cr(VI)/m^3^
Cohen et al. (1974) | Chrome plating | MED | Prevalence (%) (with grading by severity) | Referent area breathing zone: 0.3 (0.1–0.4) μg Cr(VI)/m^3^

1 mg CrO_3_ = 0.52 mg Cr(VI).

#### 4.2.1.2 Lower Respiratory Tract Effects

All five human studies meeting PECO criteria were categorized as low confidence for lower respiratory tract effects (Zhang et al., 2022; Sobaszek et al., 1998; Lindberg and Hedenstierna, 1983; Li et al., 2015b; Kuo et al., 1997b). Quantitative data for observed associations between Cr(VI) exposure and human pulmonary function were inadequate for dose-response. A lack of air or biomarker measurements in the study of stainless-steel welders (Sobaszek et al., 1998), inability to rule out substantial contribution of Cr(III) exposure to biomarker measurements (or extrapolate biomarker chromium to air Cr(VI) measurements) (Zhang et al., 2022), and potential for residual confounding in the other studies (Lindberg and Hedenstierna, 1983; Li et al., 2015b; Kuo et al., 1997b) raised concerns about the ability of these studies to appropriately characterize respiratory effects.

Table 4-10 outlines the rodent inhalation studies for lower respiratory tract endpoints in rodents that met PECO criteria (see Section 3.2.1). There were dose-response relationships in some data by (Glaser et al., 1985; 1990), but there were statistical and methodological issues with these studies (see Section 3.2.1.2). Kim et al. (2004) did not report quantitative data for chromium particle size and effects, and (1986b; Johansson et al., 1986a) and Cohen et al. (2003) only used a single high exposure group. Quantitative noncancer data by Nettesheim et al. (1971) were not provided.

Despite availability of dose-response data, there are pharmacokinetic factors that make it challenging to use inhaled Cr(VI) data in rodents to estimate site-specific respiratory effects in humans. The ascorbate concentration in rodent lungs is almost 10× higher than in human lungs, and rats are estimated to reduce Cr(VI) 10‒20× more effectively in the lung than humans (Krawic et al., 2017). This is because rodents internally synthesize their own ascorbate, a reducing agent for Cr(VI), whereas humans do not. Extrapolation between rodents and humans would require additional pharmacokinetic adjustment for lung reduction to account for the added susceptibility in humans. Such inhalation models are unavailable. Even if models were available, residual uncertainty would still persist given the weak inhalation database for these and other effects. Due to a lack of adequate quantitative human data, and the inability to extrapolate the inhalation effects across species given the pharmacokinetic differences, a lower respiratory tract RfC was not derived.

Table 4-10 Design features of inhalation studies that examined effects in animals

Study reference (confidence)^a^ | Species/strain and sex | Exposure duration | Dose groups^b^ | Animals / group | Chemical and particle size | Concentration range (mg/m^3^ Cr[VI])
Glaser et al. (1990) (medium and low) | Wistar Rat, Male | 30/90 d (22 hr/d, 7 d/wk) | 4 | 10 | Sodium dichromate; MMAD 0.28 (±1.63 GSD) μm (bottom two dose groups); MMAD 0.39 (±1.72 GSD) μm (high dose groups) | 0.05–0.4
Glaser et al. (1986) (low and uninformative) | Wistar Rat, Male | 18 mo (22 hr/d, 7 d/wk) | 3 | 99 | Sodium dichromate; MMD 0.36 (±1.69 GSD) μm | 0.025–0.1
Glaser et al. (1985) (medium) | Wistar Rat, Male | 28/90 d (22 hr/d, 7 d/wk) | 3 | 10 | Sodium dichromate; MMD 0.2 (±1.5) μm | 0.025–0.2
Johansson et al. (1986b); Johansson et al. (1986a) (medium and low) | Rabbit, Male | 4–6 wk (inexact), 6 hr/d, 5 d/wk | 1 | 8 | Sodium dichromate; MMAD 1 μm (approximate) | 0.9
Cohen et al. (2003) (medium) | F344 Rat, Male | 48 wk, 5 hr/d, 5 d/wk | 1 | 30 | Calcium chromate; MMAD 0.6 (±1.7 GSD) μm | 0.36
Kim et al. (2004) (medium and low) | Sprague-Dawley Rat, Male | 90 d, 6 hr/d, 5 d/wk | 3 | 5 | Chromium trioxide (size not reported) | 0.2–1.25
Nettesheim et al. (1971) (low) | C57BL/6 Mouse, both sexes | Lifetime, 5 hr/d, 5 d/wk | 1 | 1,090 | Calcium chromate (tabular size distribution reported, approximately 90% were <0.5 μm) | 13

MMAD = mass median aerodynamic diameter; GSD = geometric standard deviation.

a Confidence listed for multiple outcomes; see Table 3-8.

b Number does not include control group.

#### 4.2.1.3 Other Effects

Inhalation data for effects outside the respiratory system are limited. Several epidemiological studies of worker populations exposed to Cr(VI), primarily exposed by inhalation, examined the relationship between certain health hazards and occupational exposure for which candidate organ/system-specific reference values were derived for the oral route (i.e., hepatic, hematological, and developmental toxicity); however, the available studies did not support dose-response analysis (see Derivation of Candidate Values in Section 4.1.3). The only animal inhalation studies reporting effects outside the respiratory tract were rated low confidence for these outcomes. No effects were observed in studies rating medium confidence for outcomes outside the respiratory tract that were determined to be a hazard in Section 3.2, including Kim et al. (2004) (liver weight and clinical chemistry) and Glaser et al. (1985) (liver histopathology). As a result, candidate values were not derived for effects outside of the respiratory tract.

### 4.2.2 Methods of Analysis

Human data by Gibb et al. (2000a), Lindberg and Hedenstierna (1983), and Cohen et al. (1974) were used to derive candidate values of upper respiratory tract effects. However, these effects could not be modeled by Benchmark Dose Software (BMDS) models or other specialized models. As noted in the analysis of nasal effects by OSHA (2006), the available human data were insufficient to relate exposures and incidence. Studies either did not have the proper study design for a quantitative analysis or lacked short-term airborne Cr(VI) exposure data over an entire employment period (OSHA, 2006). Because none of the available studies provided data for a no-observed-adverse-effect-level (NOAEL), PODs were derived using lowest-observed-adverse-effect-levels (LOAELs) (see Table 4-11). How these uncertainties were accounted for in the quantitative derivation of the candidate values are described later in this section.

The adjustment factors to account for differences between occupational exposures and non-occupational exposure follow EPA guidelines (U.S. EPA, 2009) that acknowledges there are differences in breathing rates between workers (10 m^3^ per 8-hour day) and non-workers (20 m^3^ per 24-hour day) and that workers are exposed 240 days per year while non-workers are exposed 365 days per year (U.S. EPA, 2011d, 2012d, 2014e, 2016b). If workplace exposure is assumed to occur 240 workdays/year:

LOAEL_H E C_ = L O A E L (μ g / m^3^) × ( VEho / VEh ) × 240 days / 365 days

where:

- LOAEL_HEC_ = the LOAEL dosimetrically adjusted to an ambient human equivalent concentration;
- LOAEL = occupational exposure level (time-weighted average);
- VEho = human occupational default minute volume (10 m^3^/8 hours); and
- VEh = human ambient default minute volume (20 m^3^/24 hours).

Table 4-11 Summary of derivation of points of departure following human inhalation exposure to Cr(VI)

Study | POD rationale | Notes and conversions | LOAEL (μg/m^3^) | % incidence at LOAEL | POD HEC (μg/m^3^)
Lindberg and Hedenstierna (1983) | Ulceration of the nasal septum. The lowest concentration for the 2–20 μg Cr(VI)/m^3^ group. There is high uncertainty in the exposure concentrations. | Table 3 | 2 | 33% | 0.66
Gibb et al. (2000a) | Ulceration of the nasal septum. The median exposure at first diagnosed nasal ulceration. | Table 1 20 μg CrO_3_/m^3^ = 10.4 μg Cr(VI)/m^3^ | 10.4 | 63% | 3.4
Gibb et al. (2000a) | Ulceration of the nasal septum. The mean exposure at first diagnosed nasal ulceration | Table 1 54 μg CrO_3_/m^3^ = 28 μg Cr(VI)/m^3^ | 28 | 63% | 9.2
Cohen et al. (1974) (related study: Cohen and Kramkowski (1973)) | Ulceration of the nasal septum. Mean air concentration for exposed groups. | Table 6 0.0029 mg Cr(VI)/m^3^ (2.9 μg Cr(VI)/m^3^) | 2.9 | 32% | 0.95

Exposure adjustment for all study concentrations to obtain POD HEC used the following occupational/nonoccupational factor: (10/20) × (240/365).

For ulceration of the nasal septum from Gibb et al. (2000a), the mean exposure concentration was over 2x the median concentration, indicating that the data are skewed. Figure 1 in Gibb et al. (2000a) indicates that certain job titles were exposed to higher Cr(VI) concentrations early in the study period, and that these job titles experienced lower exposure for most of the later years in the timeline. The median result was chosen instead of the mean for this dataset, because the median is a better estimate of the central tendency for these data.

### 4.2.3 Derivation of Candidate Values

The reference concentration (RfC) is the inhalation concentration likely to be without an appreciable risk of deleterious noncancer health effects during a lifetime (U.S. EPA, 1994).

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes [(U.S. EPA, 2002); see Section 4.4.5], five possible areas of uncertainty and variability were considered. An explanation of the five possible areas of uncertainty and variability follows.

- An intraspecies uncertainty factor, UF_H_, of 3 to account for variation in susceptibility across the human population and the potential that the available data may not be representative of individuals who are most susceptible to the effect. The populations evaluated were mostly adult male workers, which is not representative of individuals who may be most susceptible to the effect. A value of UF_H_ = 3 (as opposed UF_H_ = 10) was applied because this is a portal--
- of-entry effect of a direct-acting corrosive, and therefore the response by different subpopulations from anatomic or pharmacokinetic/pharmacodynamic variability is unlikely to differ (NRC, 2001).
- An interspecies uncertainty factor, UF_A_, of 1 was applied because results were derived from studies in humans.
- A subchronic-to-chronic uncertainty factor, UF_S_, of 3 was applied. While data were not from chronic lifetime exposures, the nasal effects were observed to have a short onset time (Gibb et al. (2000a) estimated a median onset time of 22 days for ulcerated nasal septum, and 172 days for perforated nasal septum). Studies were generally consistent in showing that these effects occur after 1–6 months of exposure. This may indicate that nasal effects occur following short-term occupational exposures to high concentrations of Cr(VI). As noted in U.S. EPA (2020b), if a POD is based on subchronic evidence, the assessment considers whether lifetime exposure could have effects at lower levels of exposure. A factor of up to 10 is applied when using subchronic studies to make inferences about lifetime exposure. However, a factor other than 10 may be used depending on the magnitude and nature of the response and the shape of the dose-response curve (U.S. EPA, 1991, 1994, 1996a, 1998a, 2002). The high incidence rate of the effect at short onset time means that there cannot be 10× higher incidence from prolonged exposure. As a result, a factor of UF_S_ < 10 was applied. Because it is possible that prolonged exposures could induce adverse nasal effects or exacerbate preexisting nasal conditions in susceptible subpopulations, a value of UF_S_ = 3 (as opposed to UF_S_ = 1) was applied.
- A LOAEL-to-NOAEL uncertainty factor, UF_L_, of 10 was applied because this endpoint had a high incidence at the lowest concentration across multiple studies. As a result, there was higher uncertainty in the exposure-response relationship at lower concentrations.
- A database uncertainty factor, UF_D_, value of 1 was applied. A large database for this endpoint exists, and nasal effects are believed to be the most sensitive noncancer effects of inhaled Cr(VI).

Table 4-12 is a continuation of Table 4-11 and summarizes the application of UFs to each POD to derive a candidate value for each data set. The candidate values presented in Table 4-12 are preliminary to the derivation of the organ/system-specific reference values. These candidate values are considered individually in the selection of a representative inhalation reference value for a specific hazard and subsequent overall RfC for Cr(VI).

Table 4-12 Effects in the lower respiratory tract and corresponding derivation of candidate values for Cr(VI)

Endpoint | POD_HEC_ (μg/m^3^) | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (μg/m^3^)
Data for effects in the nasal cavity in humans
Ulceration of the nasal septum (median) Gibb et al. (2000a) | 3.4 | LOAEL | 1 | 3 | 10 | 3 | 1 | 100 | 3.4 × 10^−2^
Nasal mucosal pathology Cohen et al. (1974) | 0.95 | LOAEL | 1 | 3 | 10 | 3 | 1 | 100 | 9.5 × 10^−3^
Ulceration of the nasal septum Lindberg and Hedenstierna (1983) | 0.66 | LOAEL | 1 | 3 | 10 | 3 | 1 | 100 | 6.6 × 10^−3^

### 4.2.4 Derivation of Organ/System-Specific Reference Concentrations

Selection of organ/system-specific toxicity values can be based on the most sensitive outcome, a clustering of values, or a combination. Each candidate value was evaluated with respect to multiple considerations, including strength of evidence, basis of the POD (i.e., BMC vs. NOAEL vs. LOAEL), and dose-response model uncertainties. A confidence level of high, medium, or low was assigned to each osRfC based on the study(ies) used to derive the candidate value, and the reliability of the associated POD and candidate value calculation(s). Confidence in the POD and candidate value calculation(s) included considerations of the quality and variability of the exposure assessment in an epidemiology study or the exposure protocols in an animal study. Moreover, higher confidence was placed in the osRfC when the POD was identified close to the range of the observed data and the magnitude of exposure was relevant to those experienced in the general U.S. population.

#### 4.2.4.1 Upper Respiratory Toxicity

As noted earlier, Cr(VI) is cytotoxic and there is high confidence that Cr(VI) induces effects at the portals of entry. Furthermore, effects in the nasal cavity of humans are well documented by occupational studies (OSHA, 2006). The osRfC for effects in the upper respiratory tract is based on ulcerated nasal septum observed by the Gibb et al. (2000a) occupational study. While the study reported multiple other nasal endpoints (irritated, perforated, and bleeding nasal septum), ulcerated nasal septum was chosen because of its severity and high incidence (63% of the cohort having the clinical finding). Gibb et al. (2000a) had higher sample sizes and better exposure data than the alternative studies by Cohen et al. (1974) and Lindberg and Hedenstierna (1983).

The Baltimore plant studied by Gibb et al. (2000a) had a rigorous personal and air monitoring system that spanned a period of decades (see Table 4-28 in Section 4.4.5). This greatly increased confidence in the reported air concentrations and worker exposures. While Lindberg and Hedenstierna (1983) used both area and personal air samplers, the recorded data only spanned 13 days. Furthermore, the defined concentration ranges (<2–20 μg Cr(VI)/m^3^) by Lindberg and Hedenstierna (1983) only constituted average workday concentrations (peak values were noted to be higher, but only limited concentration data are presented). Characterization of the nasal endpoints by Cohen et al. (1974) were highly detailed, and the study employed only air measurements consistent with current NIOSH recommendations (NIOSH, 2013, 2020).^78^ However, the sample size was small, and the breathing-zone air samples represented only a snapshot in time (and not the long-term exposure of the workers over time). The osRfC for upper respiratory tract effects is based on the LOAEL for ulcerated nasal septum in humans reported by Gibb et al. (2000a), resulting in an osRfC of 3 × 10^−2^ μg/m^3^ (rounded from 3.4 × 10^−2^ μg/m^3^), or 3 × 10^−5^ mg/m^3^ (see Table 4-13). Because only LOAELs could be obtained from the datasets, and because the estimated effect incidences were high at the LOAEL (63%), there is uncertainty in the dose-response relationship at lower concentrations. For the Gibb et al. (2000a) study, effects in the nasal cavity were observed after a few months of exposure (median time on the job of 86–418 days), and it is unknown how the effect severity may increase over a lifetime of exposure. These factors decrease confidence in the osRfC for upper respiratory tract effects. Additional uncertainties relevant to upper respiratory tract effects are described in detail in Section 4.2.6. Factors that increase confidence in the osRfC for upper respiratory tract effects include the consistency at which this effect was observed (generally between 2–20 μg Cr(VI)/m^3^ with early onset time), and the thorough air sampling programs implemented for the Baltimore Cohort (see Table 4-28) (Gibb et al., 2000a).

Table 4-13 Organ/system-specific reference concentrations (RfCs) and overall RfC for Cr(VI)

Effect | Basis | osRfC mg/m^3^ | Exposure description | Confidence
Upper respiratory | Ulcerated nasal septum of humans Gibb et al. (2000a) | 3 × 10^−5^ | Occupational exposure | Medium
Overall RfC | Ulcerated nasal septum | 3 × 10^−5^ | Occupational exposure | Medium

Additional study considerations supporting the choice of the Baltimore cohort data (Gibb et al., 2000a) include physiochemical properties of the chemicals to which workers were exposed. The current database encompasses chrome plating facilities where humans were occupationally exposed to chromic acid mists (Lindberg and Hedenstierna, 1983; Cohen et al., 1974), and a chromate production plant where humans were exposed to a variety of chromium compounds in dust form (Gibb et al., 2000a); (Hayes et al., 1979). Nasal effects were observed in both types of workplaces, with candidate values derived from chrome plating facilities being the lowest. While direct comparisons of datasets are made difficult by study design differences and the fact that only LOAELs (and not NOAELs) could be determined, it is possible that nasal effects of inhaled Cr(VI) in chrome plating facilities may be exacerbated by the low pH of the chrome plating baths from which the chromic acid mists originate.

Because residential properties may be located in close proximity to chrome plating facilities, both aerosols within chromate production facilities (formed as dusts) and aerosols from chrome platers (formed as mists) are considered relevant to environmental exposure to Cr(VI). Neither is considered more representative of environmental exposure than the other. Though there are factors unique to each of the two industrial exposure scenarios (i.e., chrome plating plants and a chromate production plant), it is uncertain whether or in what ways these factors impact the effect of Cr(VI) exposure on the upper respiratory system. Based on notable study strengths such as the extensive exposure data and larger sample size, the dose-response data from the chromate production facility [specifically, Gibb et al. (2000a)] likely provides a better estimate of Cr(VI)-specific nasal toxicity than the two studies conducted in chrome plating facilities.

### 4.2.5 Selection of the Overall Reference Concentration

An overall RfC of 3 × 10^−5^ mg/m^3^ was selected. The overall RfC was based on effects in the upper respiratory tract (ulceration of the nasal septum). This is believed to be the most sensitive effect in humans, and the RfC will be protective of noncancer lower respiratory tract effects and systemic effects of inhaled Cr(VI). Additional considerations of uncertainty associated with this RfC are noted here and below in Section 4.2.6. It was derived using a LOAEL, where the incidence of the effect was high and the time of onset relatively short. The occupational cohort (Gibb et al., 2000a) consisted of a population of mostly adult males and may not have included sensitive individuals. It is uncertain if or how the endpoint severity may be affected by lifetime chronic exposures.

### 4.2.6 Uncertainties in the Derivation of Reference Concentration

#### 4.2.6.1 Onset Time for Nasal Effects

The time between first exposure and development of nasal effects varies depending on the severity of the effect, but nasal effects generally occur within 1 year of initial exposure for more severe effects, and 1–3 months for less severe effects. Gibb et al. (2000a), the only prospective study of the development of nasal effects reported the time to event in days (mean [median]) for irritation (89 [20]), ulceration (86 [22]), perforation of the septum (313 [172]), and bleeding nasal septum (418 [92]) (Gibb et al., 2000a). Cross-sectional studies reported a similar time to event periods based on self-reported interview data (Lindberg and Hedenstierna, 1983; Cohen et al., 1974). Cohen et al. (1974) reported that severity of pathology increased with longer exposure times and prevalence of ulceration or perforation in the study population was higher at 94% in workers who had worked at the plant for more than 1 year at the time data were collected compared with 57% among workers who had worked for less than a year at the same plant. More recently, Singhal et al. (2015) showed that severity of nasal outcomes increased with years of exposure in both chromate manufacturing and chrome electroplating workers. The early onset-time, combined with the fact that incidences were high at the lowest concentration (the lowest concentration in this occupational setting is still high relative to environmental levels) leads to uncertainty in the extrapolation from occupational exposure to continuous lifetime exposure.

#### 4.2.6.2 Hand-to-Nose Transfer

Only one of the candidate value studies reported hand-to-nose transfer of Cr(VI) originating from surface touching (Cohen et al., 1974). Surface contamination of Cr(VI) throughout workplace environments (including on gloves and other personal protective equipment), and detection of Cr(VI) on the hands of employees have been documented (Lucas and Kramkowski, 1975; Cohen and Kramkowski, 1973; Ceballos et al., 2017). However, no quantitative data were available to adjust for this potential route of exposure.

#### 4.2.6.3 Susceptible Populations

Quantitative analysis of effects in the lower respiratory tract were based on animal data, while analysis of effects in the upper respiratory tract were based on occupational studies of adult humans. Data for these effects were not available in susceptible populations, such as children or those with preexisting respiratory conditions.

#### 4.2.6.4 Particle size distribution

Differences in particle size across studies increase uncertainties when comparing alternative PODs. Particle size distributions in the air vary between industries or between different processes within the same industrial plant (OSHA, 2006). Neither the Gibb et al. (2000a) study nor the other studies considered for dose-response (Lindberg and Hedenstierna, 1983);(Cohen et al., 1974) characterize particle size. A chromate production facility in Painesville, OH Bourne and Yee (1950) reported median aerodynamic equivalent diameter (AED) of in-plant airborne dust to be 1.7 μm. Across multiple chromate production facilities (which included the Baltimore plant that is the subject of the Gibb et al. (2000a) study), PHS (1953) estimated geometric mean particle sizes of 0.35 μm, with a standard geometric deviation of 0.18 μm. In chrome plating facilities, Kuo et al. (1997a) measured mass median diameter (MMD) of 1.07–6.38 μm from area sampling and 0.75–4.73 μm from personal sampling. While large particles (>5 μm in diameter) are more likely to be trapped in the nasal mucosa, ultrafine particles (>0.1 μm) are still capable of depositing in the nasal passages (ICRP, 1994; Hinds, 1999b). Furthermore, the hygroscopic nature of chromium particles (which can lead to diameter growth in the humid respiratory airways (Asgharian, 2004)), may increase nasal deposition (Youn et al., 2016).

### 4.2.7 Confidence Statement

An overall confidence level of High, Medium, or Low was assigned to reflect the level of confidence in the study(ies) and hazard(s) used to derive the RfC, the overall database, and the RfC itself, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994).

The confidence in the overall chronic RfC is medium. The RfC for upper respiratory tract effects is based on the LOAEL for ulcerated nasal septum in humans reported by Gibb et al. (2000a), resulting in an RfC of 3 × 10^−5^ mg/m^3^. While there is high confidence that inhaled Cr(VI) can induce effects in the nasal cavity of humans, quantitative characterization of these endpoints has uncertainties. The available studies did not have enough exposure groups or individual-level data adequate for a dose-response analysis, and only LOAELs could be obtained from all the available datasets. For the Gibb et al. (2000a) study, effects in the nasal cavity were observed after a few months of exposure (median time on the job of 86–418 days), and it is unknown how the effect severity may increase over a lifetime of exposure. Because the estimated effect incidences were high at the LOAEL (63%), there is uncertainty in the dose-response relationship at lower concentrations. As a result, the confidence in the RfC for upper respiratory effects is medium.

### 4.2.8 Previous IRIS Assessment: Inhalation Reference Concentration

The previous IRIS assessment contained two RfCs for Cr(VI). An RfC for “chromic acid mists and dissolved hexavalent chromium aerosols” and an RfC for “hexavalent chromium dusts” were posted on the IRIS database in 1998 (U.S. EPA, 1998c). The 1998 RfC for Cr(VI) acid mists and dissolved aerosols was based on the human study by Lindberg and Hedenstierna (1983). A LOAEL for nasal septum atrophy of 2 μg/m^3^ was identified based on the lower bound of the 2‒20 μg/m^3^ range, and this value was adjusted using a continuous exposure adjustment factor, and an adjustment factor for occupational and 24-hour average breathing rates. This resulted in a LOAEL for continuous exposure of 0.714 μg/m^3^. A total uncertainty factor of 90 was applied: 3-fold for extrapolation from a subchronic to a chronic exposure, 3-fold for extrapolation from a LOAEL to a NOAEL, and 10-fold for interhuman variation. This resulted in an RfC of 0.008 μg/m^3^ (8 × 10^−6^ mg/m^3^) for hexavalent chromic acid mists and dissolved hexavalent chromium aerosols. The current assessment derived a different LOAEL for the Lindberg and Hedenstierna (1983) study, because most cases (7/8) of nasal ulceration in the 2‒20 μg/m^3^ group had peak exposure levels at or above 20 μg/m^3^.

The previous RfC for Cr(VI) dusts was based on the studies by Glaser et al. (1985); (1990) and used the modeling and data analysis of this dataset published by (Malsch et al., 1994). Malsch et al. (1994) developed BMCs for lung weight, lactate dehydrogenase (LDH) in BAL fluid, protein in BAL fluid, albumin in BAL fluid, and spleen weight. The Malsch et al. (1994) analysis defined the benchmark concentration as the 95% lower confidence limit on the dose corresponding to a 10% relative change in the endpoint compared with the control. A continuous exposure adjustment factor was applied, and the maximum likelihood model was used to fit continuous data to a polynomial mean response regression, yielding maximum likelihood estimates of 36–78 μg/m^3^ and BMCs of 16–67 μg/m^3^. LDH was the most sensitive endpoint (BMC of 16 μg/m^3^) and was the basis of the 1998 IRIS assessment RfC for Cr(VI) dusts. An RDDR of 2.1576, derived by methods outlined in U.S. EPA (1994), was applied to this value to extrapolate a human equivalent concentration. A total uncertainty factor of 300 was applied: 10-fold for the less-than-lifetime exposure, 10-fold for variation in the human population, and 3-fold to account for pharmacodynamic differences not accounted for by the RDDR. This resulted in an RfC of 1 × 10^−4^ mg/m^3^ for hexavalent chromium dusts.

## 4.3 ORAL SLOPE FACTOR FOR CANCER

The oral slope factor (OSF) is a plausible upper bound on the estimate of risk per mg/kg-day of oral exposure. The OSF can be multiplied by an estimate of lifetime exposure (in mg/kg-day) to estimate the lifetime cancer risk. EPA determined, under the 2005 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), that Cr(VI) is “likely to be carcinogenic to humans” via the oral route of exposure.

### 4.3.1 Analysis of Carcinogenicity Data

The animal database for cancer consisted of a chronic 2-year drinking water bioassay which found “clear evidence of carcinogenic activity” of Cr(VI) in male and female rats and mice (NTP, 2008). These results were based on increased incidences of squamous cell neoplasms in the oral cavity of rats and increased incidences of neoplasms in the small intestine of mice. The data from NTP (2008) indicate a dose-response relationship in both species. The cancer data for dose-response are provided below in Table 4-14. Additional data of tumor subtypes are available in Section 3.2.3.2.

Table 4-14 Dose-response data on neoplastic lesions in the gastrointestinal tracts of rats and mice (NTP, 2008)

Tumor type and species/sex | | Administered mg/L Cr(VI), mg/kg-d Cr(VI)^a^, and incidence/total
Male B6C3F1 mice | | 0 mg/L | 5 | 10 | 30 | 90
Male B6C3F1 mice | | 0 mg/kg-d | 0.450 | 0.914 | 2.40 | 5.70
Male B6C3F1 mice | | 0 mg/kg-d ^b^ | 0.0700 | 0.149 | 0.443 | 1.29
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence / Total^c^ | 1/50 | 3/49 | 2/49 | 7/50^d^ | 20/50^d^
Female B6C3F1 mice | | 0 mg/L | 5 | 20 | 60 | 180
Female B6C3F1 mice | | 0 mg/kg-d | 0.302 | 1.18 | 3.24 | 8.89
Female B6C3F1 mice | | 0 mg/kg-d ^b^ | 0.0463 | 0.197 | 0.636 | 2.31
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence / Total^c^ | 1/49 | 1/50 | 4/49 | 17/50^d^ | 22/49^d^
Male F344 rats | | 0 mg/L | 5 | 20 | 60 | 180
Male F344 rats | | 0 mg/kg-d | 0.200 | 0.796 | 2.10 | 6.07
Squamous cell carcinoma or papilloma (oral mucosa or tongue) | Incidence / Total^c^ | 0/50 | 1/47 | 0/47 | 0/50 | 7/49^d^
Female F344 rats | | 0 mg/L | 5 | 20 | 60 | 180
Female F344 rats | | 0 mg/kg-d | 0.248 | 0.961 | 2.60 | 7.13
Squamous cell carcinoma (oral mucosa or tongue) | Incidence / Total^c^ | 1/50 | 1/50 | 0/50 | 2/50 | 11/50^d^

a Time-weighted average daily doses calculated from NTP water consumption data.

b PBPK-derived internal dose in mg/kg-d Cr(VI) escaping gastric reduction.

c Tumor incidences adjusted based on the number of animals surviving beyond 365 days.

d Denotes significant difference from the control group reported by NTP (2008) using the Poly-3 test (p < 0.05).

Human dose-response data for cancer via the oral route were not suitable for dose-response analysis. The lack of individual estimates of exposure, the uncertain nature of the mortality data, and the potential impact of confounding made it difficult to draw conclusions (see Section 3.2.3). Human cancer data via the inhalation route of exposure were not used for oral slope factor derivation because route-to-route extrapolations were not considered in this assessment (see Protocol, Appendix A).

### 4.3.2 Derivation of the Oral Slope Factor

The lifetime oral cancer slope factor for humans is defined as the slope of the line from the lower 95% bound on the exposure at the POD to the control response [slope factor = 0.1/HED(BMDL_10_) for a BMR of 10% extra risk or 0.01/HED(BMDL_01_) for 1% risk]. This slope, a 95% upper confidence limit, represents a plausible upper bound on the true risk. Using dosimetric extrapolation from the HED(BMDL_10_) and HED(BMDL_01_), human equivalent oral slope factors were derived for each sex/tumor site combination. Results for all tumor types are listed in Table 4-15.

Table 4-15 Summary of the oral slope factor derivations

Species (sex) | Model | BMR | BMD mg/kg-d^a^ | BMDL mg/kg-d^a^ | Extrapolation Method | BW^3/4^-scaled internal dose POD mg/kg-d^b^ | POD_HED_ mg/kg-d^c^ | OSF (mg/kg-d)^−1^
Adenomas or Carcinomas in the mouse small intestine ( NTP, 2008 )
Mice (M) | 1° MS^d^ | 10% ER | 0.301 | 0.218 | PK | 0.0345 | 0.345 | 0.290
Mice (M) | 1° MS^d^ | 10% ER | 1.44 | 1.05 | BW^3/4^ | N/A | 0.166 | 0.602
Mice (M) | 1° MS | 1% ER | 0.0288 | 0.0208 | PK | 0.00329 | 0.0931 | 0.107
Mice (M) | 1° MS | 1% ER | 0.137 | 0.100 | BW^3/4^ | N/A | 0.0158 | 0.633
Mice (F) | 1° MS | 10% ER | 0.320 | 0.243 | PK | 0.0384 | 0.361 | 0.277
Mice (F) | 1° MS | 10% ER | 1.34 | 1.03 | BW^3/4^ | N/A | 0.163 | 0.613
Mice (F) | 1° MS | 1% ER | 0.0305 | 0.0232 | PK | 0.00367 | 0.102 | 0.098
Mice (F) | 1° MS | 1% ER | 0.128 | 0.0986 | BW^3/4^ | N/A | 0.0156 | 0.641
Squamous cell carcinoma or squamous cell papilloma in oral mucosa or tongue ( NTP, 2008 )
Rats (M) | 1° MS | 10% ER | 6.04 | 3.37 | BW^3/4^ | N/A | 0.923 | 0.108
Rats (M) | 1° MS | 1% ER | 0.576 | 0.321 | BW^3/4^ | N/A | 0.0879 | 0.114
Rats (F) | 1° MS | 10% ER | 4.25 | 2.70 | BW^3/4^ | N/A | 0.645 | 0.155
| 1° MS | 1% ER | 0.406 | 0.257 | BW^3/4^ | N/A | 0.0614 | 0.163

a Details of BMD analyses are provided in Appendix D. Units of administered (BW^3/4^ extrapolation) or dose escaping stomach reduction (internal dose used for PK extrapolation of mouse tumors) mg/kg-d Cr(VI) dose.

b BW^3/4^ scaling adjustment of the internal mouse dose BMDL (dose escaping reduction). The BMDL was multiplied by (BW_A_/BW_H_)^1/4^, where BW_H_ = 80 kg and BW_A_ is set to the study-specific time-weighted average (TWA) value of 0.05 kg for male and female mice at the 2-year time period in NTP (2008) (the same study-specific BW value was used in the PK modeling).

c POD_HED_ in units of mg/kg-d Cr(VI) oral dose ingested by humans. For the PK extrapolation in mice, this is the mean value of 2000 Monte Carlo human PK simulations needed to achieve the internal dose POD (see Appendix C.1.5 for details). For the BW^3/4^ extrapolation method, the ingested rodent dose BMDL (total administer dose) was multiplied by (BW_A_/BW_H_)^1/4^, where BW_H_ = 80 kg and BW_A_ is set to the study-specific time-weighted average (TWA) value with TWA BW_A_ = 0.05 kg for male and female mice, 0.450 kg for male rats, TWA BW_A_ = 0.260 kg for female rats at the 2-year time period in NTP (2008), with no additional adjustment.

d MS = Multistage model (1° MS indicates first degree multistage model).

The OSF for Cr(VI), 0.155 (mg/kg-day)^−1^, which rounds to 0.16 (mg/kg-day)^−1^, was derived from oral tumors in female rats by performing the dose-response analysis with the applied dose for a 10% BMR and then BW^3/4^ scaling of the resulting POD_rat_ to obtain the scaled POD_HED_. The OSF values derived from independent analyses of small intestine tumors in male and female mice, using PBPK-predicted internal doses and a BMR of 1%, are very similar, and the average of both values is 0.103 (mg/kg-day)^−1^. An OSF almost identical to that obtained for mouse small intestine tumors is obtained based on male rat oral tumors (with only BW^3/4^ scaling): 0.108 (mg/kg-day)^−1^. Because of nonlinearity in the human PK predictions, extrapolation of mouse intestinal tumors starting with a BMR of 10% leads to an average OSF of 0.284 (mg/kg-day)^−1^. The nonlinearity occurs because depletion of reducing cofactors is predicted such that an increase of approximately 10-fold internal dose only requires an increase of about 3.5-fold in ingested dose for humans in the range of BMDL_01_ to BMDL_10_. For comparison, the OSF based on mouse small intestine tumors derived with BW^3/4^ scaling without PBPK modeling is approximately 0.6 (mg/kg-day)^−1^. As there are no data to support any one tumor type (rat oral cavity or mouse small intestine) as most relevant for extrapolating to humans, the most sensitive result for GI tract tumors (after accounting for expected nonlinearity in stomach reduction) was used to derive the oral slope factor. The OSF for female rat oral tumors rounds to 0.16 (mg/kg-day)^−1^ whether a BMR of 10% of 1% is used.

The difference between the OSF for small intestine tumors obtained using the PBPK-predicted dosimetry and standard BW^3/4^ scaling occurs because human adults with average gastric conditions are more effective at reducing Cr(VI) at low doses than rodents. However, this difference is greatest at lower doses where no depletion of cofactors involved in the reduction of Cr(VI) is expected. This larger difference in reduction at low doses results in a larger difference in the estimated rodent/human susceptibility, and a lower oral slope factor.

The final oral slope factor of 0. 16 (mg/kg-day)^−1^, based on oral tumors in rats, represents an upper bound on the slope factor at low doses (since it is calculated as BMR/POD_HED_ using a lower bound on the POD_HED_ for 1% or 10% extra risk) for adult exposure to Cr(VI) (adjustment for childhood exposure to a mutagen is addressed below). It is not protective of children, the elderly, or other sensitive groups discussed in Section 3.3.1.

For BW^3/4^ scaling adjustment and PBPK modeling applied above, the mean body weight recommended by EPA’s Exposure Factors Handbook (U.S. EPA, 2011a) (80 kg) was used. There is a negligible difference in the PODs when using 70 kg (U.S. EPA, 1988) or 80 kg, and the final OSF would be the same under either assumption.

### 4.3.3 Dose-Response Analysis–Adjustments and Extrapolations Methods

A benchmark dose (BMD) approach was used to model the dose-response data. This method is described in detail in Section 4.1.2. Because a mutagenic mode-of-action (MOA) for Cr(VI) carcinogenicity via the oral route of exposure (see Section 3.2.3) is “sufficiently supported in (laboratory) animals” and “relevant to humans,” EPA considers a linear low dose extrapolation from the POD in accordance with Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a). However, because of the nonlinearity between ingested dose and total chromium concentration in the intestinal tissue, discussed in Section 3.1.2.2, which is addressed by the gastric PBPK model (see Section 3.1.2), the dose-response analysis for small intestine (SI) tumors should be based on the “internal” dose predicted by the PBPK model, i.e., the dose escaping reduction in the stomach. As shown in Section 3.1.2.2, the relationship between induced total chromium concentration in the mouse duodenum and the PBPK-predicted dose escaping reduction is essentially linear. The increase in total tissue chromium above background is presumed to be proportional to the total flux of Cr(VI) into the tissue, which is assumed in turn to be proportional to cancer risk. Therefore, the PBPK-predicted intestinal dose was used for evaluation and extrapolation of the mouse SI tumor data. Since exposure to oral cavity tissues is direct, without opportunity for reduction to occur first, the unadjusted ingested dose is used for evaluation and extrapolation of the rat oral tumor data.

The multistage model was then selected for dose-response analysis because it is consistent with low dose linearity, it is sufficiently flexible for most cancer bioassay data, and its use provides consistency across cancer dose-response analyses (Gehlhaus et al., 2011). Graphical results are provided in Figure 4-4 below. Further details, including the modeling outputs, can be found in (U.S. EPA, 2021a).

Figure 4-4 BMDS 3.2 graphical output of selected models for dose-response of cancer data in male and female rats and mice from NTP (2008).

All selected models are first degree multistage. Linear extrapolation indicates the extrapolation at the BMDL using a BMR of 10%. Mouse SI tumor analysis used the PBPK-derived internal doses.

BMD analysis was performed with both a BMR of 10% and a BMR of 1% to evaluate possible nonlinearities in the dose-response relationship (see Table 4-15). The 1% BMR was specifically tested in order to evaluate response in the range of PBPK-predicted internal doses for which the dosimetry in humans is approximately linear for the intestinal tumor response. For female mice the intestinal tumor BMDL10 was 0.243 mg/kg-day and the BMDL_01_ was 0.0232 mg/kg-day, while for male mice the intestinal tumor BMDL_10_ = 0.218 mg/kg-day and the BMDL_01_ = 0.0208 mg/kg-day. Thus, for both male and female mice the BMDL is close to proportional to the BMR, consistent with the assumption of low-dose linearity in the tumor response. The estimated tumor risk per unit internal dose is almost identical for BMDL_01_ vs. BMDL_10_, though 5% higher using BMDL_01_. Given that the risk per unit internal dose is equivalent but that the BMDL_01_ values (after allometric scaling as described just below) are in the range where human dosimetry is linear, while the BMDL_10_ values are in the dosimetric nonlinear range, the results obtained with a BMR of 1% were selected for extrapolation to humans. A BW^3/4^-adjustment was then applied to the Cr(VI) dose that is estimated to escape gastric reduction in the mice to account for the expectation that subsequent clearance of Cr(VI), after it is absorbed into human tissues, will be slower than in mice.

The human gastric PBPK model was then used to estimate the human equivalent dose, using the same methodology applied for noncancer effects (see Section 4.1.2). Specifically, the mean human ingested dose from the PBPK Monte Carlo analysis was used as the PODHED for the OSF, as opposed to the lower 1% ingested dose (which was used for the POD of the RfD). This is because intraspecies variability in pharmacokinetics and pharmacodynamics is not incorporated into cancer risk assessment (U.S. EPA, 2006c), with the exception for early-life considerations noted in the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b). Uncertainty factors are not applied during rodent-to-human extrapolation of cancer dose-response data. For comparative purposes, the BW^3/4^ scaling approach without human PK Cr(VI) gastric reduction modeling or Monte Carlo analysis is also presented. This can be interpreted as the result for a susceptible subpopulation having high gastric pH (>4.0) resulting in an extent of Cr(VI) gastric juice reduction capacity equal to that in mice (see Appendix C.1.5).

For tumors in the oral cavity of rats, there is uncertainty regarding the appropriate internal dose metric. Mice did not exhibit tumors of the oral cavity, but in a separate bioassay were observed to have higher oral tissue chromium levels than rats following 90-day drinking water exposure (Kirman et al., 2012). Mice rarely exhibit oral tumors from NTP bioassays, even for chemicals inducing oral tumors in rats (NTP, 2008; Ibrahim et al., 2021).^79^ Thus, mice may be less susceptible to tumors of the oral cavity due to factors that cannot be accounted for using PBPK modeling. There were no observed nonneoplastic lesions in the oral mucosa of rats or mice following either the chronic or subchronic high dose NTP Cr(VI) drinking water bioassays (Witt et al., 2013). Unlike for the mouse, where tumors were observed in GI organs posterior to the stomach (where most Cr(VI) reduction occurs), tumors of the rat oral cavity occur in tissues where Cr(VI) exposure is not mitigated by extracellular reduction in the stomach. As a result, species differences in Cr(VI) reduction in the stomach are not relevant for the dose-response analysis of rat oral tumors. Site-specific PBPK models of Cr(VI) kinetics in the oral cavity epithelium are not available. In the absence of an adequately developed theory or information to develop and characterize an oral portal-of-entry dosimetric adjustment factor, application of BW^3/4^ scaling is recommended (U.S. EPA, 2005a, 2011c).

### 4.3.4 Application of Age-Dependent Adjustment Factors

Because a mutagenic mode-of-action for Cr(VI) carcinogenicity is sufficiently supported in laboratory animals and is relevant to humans (see Section 3.2.3), and in the absence of chemical-specific data to evaluate differences in age-specific susceptibility, increased early-life susceptibility to Cr(VI) is assumed and ADAFs should be applied, as appropriate, in accordance with the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b). The oral slope factor of 0.16 (mg/kg-day)^−1^ (rounded from 0.155 (mg/kg-day)^−1^) is calculated from data for adult exposures and dosimetry; chemical-specific data to address early-life susceptibility are not available for Cr(VI). Example calculations for estimating cancer risks based on age at exposure are provided in Section 6 of the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b).

The Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens establishes ADAFs for three specific age groups. The current ADAFs and their corresponding age groups are 10 for exposed individuals <2 years old, 3 for exposed individuals 2 to <16 years old, and 1 for exposed individuals ≥16 years old (U.S. EPA, 2005b). The 10- and 3-fold adjustments to the slope factor are to be combined with age-specific exposure estimates when estimating cancer risks from early-life (<16 years of age) exposures to Cr(VI).

To illustrate the use of the ADAFs established in the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b), OSF calculations are presented for three exposure duration scenarios, including full lifetime. For oral exposures assuming Cr(VI) exposure-response equivalence across age groups (i.e., equivalent risk from equivalent exposure levels, independent of body size), the ADAF calculation is fairly straightforward. The partial and lifetime risks (per mg/kg-day) are presented below in Table 4-16.

Table 4-16 Application of ADAFs for 70-year exposure to Cr(VI) from ages 0 to 70

Age group | ADAF | Slope factor (mg/kg-d)^−1^ | Duration adjustment | Partial slope factor (mg/kg-d)^−1^
0–<2 yr | 10 | 0.16 | 2 yr/70 yr | 0.046
2–<16yr | 3 | 0.16 | 14 yr/70 yr | 0.096
≥16 yr | 1 | 0.16 | 54 yr/70 yr | 0.123
Total slope factor (mg/kg-d)^−1^ | | | | 0.265

Note that the partial slope factor for each age group is the product of the values in columns 2–4 (e.g., 10 × 0.16 (mg/kg-day)^−1^ × 2/70 = 0.046 (mg/kg-day)^−1^ for exposures from age 0 to <2 years), and the total slope factor is the sum of the partial slope factors. Thus, an estimate of the lifetime OSF for exposure starting at birth is (after rounding) 0.27 (mg/kg-day)^−1^.

If calculating the cancer risk for a 30-year exposure to a constant average daily dose of 0.0001 mg Cr(VI)/kg-day from ages 0 to 30 years, the duration adjustments would be 2/70, 14/70, and 14/70, and the partial risks would be (10 × 0.16 × 0.0001 × 2/70 = 4.6 × 10^−6^), (3 × 0.16 (mg/kg-day)^−1^ × 0.0001 (mg/kg-day) × 14/70 = 9.6 × 10^−6^), and (1 × 0.16 (mg/kg-day)^−1^ × 0.0001 (mg/kg-day) × 14/70 = 3.2 × 10^−6^), resulting in a total risk estimate of 1.7 × 10^−5^.

The slope factor of 0.16 (mg/kg-day)^−1^ applies to risks from exposures to adults for a lifetime (70 years). If calculating the cancer risk for an adult exposure to a constant average daily dose of 0.0001 mg Cr(VI)/kg-day for 30 years (e.g., from ages 20 to 50 years), the duration adjustments would be 0/70, 0/70, and 30/70, and the partial risks would be 0, 0, and (1 × 0.16 (mg/kg-day)^−1^ × 0.0001 (mg/kg-day) × 30/70 = 6.9 × 10^−6^), resulting in a total risk estimate of 6.9 × 10^−6^.

ADAF adjustment calculations assume a constant exposure. For oral exposures, the calculation of risk estimates adjusted for potential increased early-life susceptibility is complicated by the fact that for a constant concentration of Cr(VI) in drinking water, doses will vary by age because of different age-specific drinking water consumption rates. Different EPA Program or Regional Offices may have different default age-specific ingestion rates that they use for risk assessments for specific exposure scenarios (such as incidental soil ingestion) that will vary due to changes in activity, contact, and ingestion rate.

### 4.3.5 Uncertainties in the Derivation of the Oral Slope Factor

Because the studies and pharmacokinetics methods used to derive the OSF are the same as those used to derive the RfD, the major qualitative uncertainties related to OSF derivation are outlined in Section 3.3 and Section 4.1.5. Additional information on susceptible populations is provided in Section 3.3.1. Briefly,

- Uncertainties persist in the PBPK models of the human and mouse stomach. Population variability in kinetic parameters is unknown, and it is likely that gastric contents and microbiota contribute to interindividual variation.
- Uncertainty in the choice of the tumor type and internal dose metric for cross-species extrapolation.
- Cr(VI) detoxification in the stomach for populations with elevated stomach pH (consumers of medicine to treat acid reflux, hypochlorhydria individuals) may differ from standard health individuals.
- There may be higher susceptibility for carriers of mutated cystic fibrosis transmembrane conductance regulator (CFTR) gene (see Sections 3.2.3.4 and 3.3.1).

Individuals taking medication to treat gastroesophageal reflux disease (GERD), including calcium carbonate-based acid reducers and proton pump inhibitors, have an elevated stomach pH during treatment. This is known to be a significant fraction of the population since up to 20% of the population is afflicted by GERD, and the gastric pH for these individuals may be above 4 throughout the day during successful treatment (Lin and Triadafilopoulos, 2015; GBD 2017, 2020; Delshad et al., 2020; Burdsall et al., 2013; Atanassoffet al., 1995). A sensitivity analysis was performed on the human model (see Appendix C.1.5), assuming a baseline stomach pH = 4 (as opposed to 1.3). It was found that for internal doses near those of the cancer PODs for mice, the mean^80^ human equivalent dose for a population with baseline gastric pH = 4 would be approximately ½ that of the standard population with baseline pH = 1.3. As a result, the OSF for this population would be approximately 2× higher than obtained in the current analysis. Similarly, the OSF estimated by default approaches (BW^3/4^ scaling and no adjustment for gastric reduction) would be health-protective for this population since that method implicitly assumes that humans and rodents have the same gastric pH (>4) and reduction capacity. After rounding, the adult-based OSF for BW^3/4^ scaling [0.6 (mg/kg-d)^−1^] is 5.45× the adult-based OSF estimated by PBPK modeling of small-intestinal tumors [0.11 (mg/kg-d)^−1^] and 3.75× the adult-based OSF obtained for female rat oral tumors [0.16 (mg/kg-day)^−1^] (without use of a PBPK model). Under the BW^3/4^ scaling assumption, the lifetime ADAF-adjusted value would be [1 (mg/kg-day)^−1^]. The infant and neonatal gastric environments and the lack of data on Cr(VI) reduction during early life stages are also significant uncertainties and are not fully addressed by the ADAF or the adult-based sensitivity analyses.

Table 4-17 provides an overview summarizing the uncertainties and their impact on the OSF.

Table 4-17 Summary of uncertainties in the derivation of oral slope factor values for Cr(VI)

Consideration | Impact on unit risk | Decision | Justification
Target organ | OSF decreases from 0.16 to 0.11 (mg/kg-d)^−1^ if the calculation is based on intestinal tumors (in the male and female mouse) instead of oral tumors (in the female rat). | Oral tumors in female rats (squamous cell carcinoma or squamous cell papilloma in oral mucosa or tongue) | Tumor site is concordant across rats and mice in the GI tract as a whole (small intestine and mouth), increasing support for its relevance to humans.; As there are no data to support any one result as most relevant for extrapolating to humans, the most sensitive result for GI tract tumors was used to derive the oral slope factor.
Data set | None | NTP (2008) | NTP (2008) is a high confidence study and the only to evaluate potential carcinogenicity in multiple organs and multiple species following chronic drinking water exposure.
Cross-species scaling dose metric | Alternatives could ↓ or ↑ slope factor | mg/kg-d Cr(VI) ingested, adjusted by BW^3/4^ scaling | The amount of Cr(VI) available for absorption in the oral cavity is a function of how much Cr(VI) is ingested since no reduction is expected before contact with the tissue.; Application of BW^3/4^ scaling accounts for the expectation that once absorbed into epithelial tissues, Cr(VI) reduction will be slower in humans than rats by this factor.
Low dose extrapolation | None:The cancer risk estimate was similar for oral tumors using either a BMR of 1% or 10%. | Linear extrapolation from POD (based on mutagenic MOA) | Available MOA data support linearity (mutagenicity is a primary MOA of Cr(VI)). See Appendix D.3 for an uncertainty analysis of the low dose extrapolation method.
Statistical uncertainty at POD | ↓ OSF 1.6-fold if BMD used as the POD rather than BMDL | BMDL (preferred approach for calculating plausible upper-bound slope factor) | Limited size of bioassay results in sampling variability; lower bound is 95% confidence interval on administered exposure at 10% extra risk of alimentary tract tumors.
Dose-response modeling | Alternatives could ↓ or ↑ slope factor | Multistage-model, 10% ER BMR for oral tumors, 1% ER BMR for intestinal tumors. | No biologically based models for Cr(VI) were available. Multistage models are sufficiently flexible for most cancer bioassay data, and their use provides consistency across cancer dose-response analyses. See Appendix Section C.1.5 for additional details on the impact of alternative dose metrics. Applying a BMR of 1% vs. 10% ER decreases the slope factor for intestinal tumors to 0.1 vs. 0.3 (mg/kg-d)^−1^ due to nonlinear human pharmacokinetics.
Sensitive subpopulations | ↑ OSF to unknown extent | ADAFs are recommended for early-life exposures | No chemical-specific data are available to determine the range of human pharmacodynamic variability or sensitivity. Deriving an OSF from populations with high baseline gastric pH would lead to a significantly higher OSF (over 2× higher).

#### 4.3.5.1 Alternate dose-response analysis and extrapolation using tissue concentration data

Tissue concentration data were collected in rats and mice exposed to Cr(VI) in drinking water at 90 days (Kirman et al., 2012), including two concentrations lower than those used in the NTP 2-year drinking water bioassays. However, after adjustments for water intake and body weight, only the lowest dose group was below the lowest NTP (2008) exposure on a mg/kg-day basis. The duodenum is the tissue where the highest Cr(VI) uptake is expected to occur in rodents, and where most Cr(VI)-induced tumors were found in the NTP (2008) 2-year drinking water bioassay. For the duodenum, tissue concentration data in Kirman et al. (2012) were below the method reporting limit (analytical results labeled “B”^81^) for all rodents at the lowest (non-control) dose. For data in the jejunum, the lowest two nonzero doses were mostly labeled “U” (result ≤ the method detection limit (MDL)) or “B.” In the ileum, all data were labeled either “U” or “B” for the lowest three nonzero doses (meaning only the three highest doses produced results with analytical certainty). An estimate of the average whole small intestine concentration as a function of dose is complicated by the more distal (and uncertain) concentrations. Because the duodenum tissue concentration data were more robust than for the distal small intestine and these data were only available in females, a limited analysis was performed for duodenum data of female mice only.

##### Tissue-based BMD modeling

Haney (2015a); (Haney, 2015b) provides a regression equation relating oral dose in female mice to duodenum concentration (C_d_):

This regression equation was used to convert NTP (2008) doses in female mice to duodenum tissue concentrations (see Table 4-18). Notably, the value of the Hill coefficient, n, obtained by (Haney, 2015a, b) was 1.4, indicating a slightly superlinear exposure-dose relationship.

Table 4-18 Extrapolated duodenum tissue concentration for the NTP (2008), using regression by (Haney, 2015a, b)

Time weighted average dose (mg/kg-d) | Extrapolated duodenum concentration (mg/kg total chromium) | Extrapolated duodenum concentration (mg/kg total chromium minus background) | Adenomas or carcinomas in duodenum | Diffuse epithelial hyperplasia in duodenum
0 | 0.018 | 0 | 0/49 | 0/42
0.302 | 1.33 | 1.31 | 0/50 | 16/42
1.18 | 7.96 | 7.95 | 2/49 | 35/48
3.24 | 23.5 | 23.5 | 14/50 | 31/42
8.89 | 44.6 | 44.6 | 18/49 | 42/48

Dose-response was performed on a basis of mg/kg added chromium in the duodenum. Because an equivalent relationship between oral dose and duodenum tissue concentration has not been developed for humans (and there is added complexity in directly comparing human and rodent duodenums due to differences in relative length), the internal dose BMDL10 for the mouse (mg/kg duodenum) was first converted to an external dose for the mouse (mg/kg-day oral dose) by calculating the inverse of the fitted tissue concentration curve, described just above. The resulting mouse external dose POD was then converted to an HED by BW^3/4^ scaling. This is the interspecies conversion method applied by (Haney, 2015a). To explore possible nonlinearities in dose-response, both the multistage and nonlinear models (typically applied to noncancer endpoints) were run. Results are outlined below in Table 4-19.

Table 4-19 Oral slope factor in female mice using extrapolated tissue concentration data

Endpoint | Model(s) | BMDL_10_ (mg/kg duodenum) | BMDL_10_ (mg/kg-d oral dose) | HED (mg/kg-d) | OSF (mg/kg-d)^−1^
Adenomas or carcinomas in female mouse duodenum | Multistage 1 and log logistic | 7.51 | 1.125 | 0.178 | 0.56

HED = mg/kg-d multiplied by (BW_A_/BW_H_)^1/4^, i.e., (0.05/80)^1/4^ = 0.1581.

OSF = 0.1/HED since the HED is for a 10% response level.

Data for duodenum hyperplasia were still not amenable to BMD modeling after converting to tissue concentrations for the same reasons outlined in Appendix D.1.1. As a result, the LOAEL and human extrapolation would remain unchanged given the available dose-response data.

For tumors of the duodenum, the log-logistic model had the lowest AIC, and the BMDL_10_ for log-logistic was equivalent to the BMDL_10_ of the multistage 1 model listed in Table 4-19 (which is preferred by the criteria in Appendix D.2.1), yielding an OSF of 0.56 (mg/kg-day)^−1^. In contrast, applying the multistage model using the applied dose for the same tumor data in female mice, and BW^3/4^ extrapolation to humans (equivalent to this alternate approach), yielded an OSF of 0.613 (mg/kg-day)^−1^ (see Table 4-15). Hence, using the log-logistic model with tissue concentrations as the dose metric (with the same BMR) and then extrapolating the result to an OSF would only reduce the OSF by 10% compared with EPA’s analysis using standard BW^3/4^ extrapolation (i.e., without application of the PBPK model). Further, the alternate approach described here (using mouse tissue concentrations as the internal dose metric) yields a slope factor that is double (0.56/0.277) that estimated from the BMDL_10_ and 5.7 times (5.6/0.098) that estimated from the BMDL_01_ for female mice using EPA’s PBPK extrapolation (see Table 4-15). A higher slope is estimated by this tissue-dose method because it does not incorporate the measured differences in gastric reduction between mice and humans that is accounted for by EPA’s gastric PBPK modeling. It is not possible to use EPA’s gastric PBPK modeling in conjunction with tissue concentrations for mouse-human extrapolation because the relationship between intestinal tissue concentration and gastric dose is not known for humans. Therefore, because this alternate approach using measured tissue doses in mice does not address the dosimetric nonlinearity in humans and does not result in an appreciable difference from EPA’s result with BW^3/4^ extrapolation, it was not considered further.

### 4.3.6 Previous IRIS Assessment: Oral Slope Factor

The previous IRIS assessment for Cr(VI) was posted to the IRIS database in 1998 (U.S. EPA, 1998c). In that assessment, EPA concluded that the oral carcinogenicity of Cr(VI) could not be determined (and was thus classified as Group D under the 1986 classification guidelines). At the time, only one study in humans suggested an association with stomach cancer, but other human and animal studies did not report similar effects. Therefore, no oral slope factor was derived.

## 4.4 INHALATION UNIT RISK FOR CANCER

The inhalation unit risk (IUR) is a plausible upper bound on the estimate of risk per μg/m^3^ air breathed. The IUR can be multiplied by an estimate of lifetime exposure (in μg/m^3^) to estimate cancer risks over a lifetime or partial lifetime.

In 1998, the EPA IRIS Toxicological Review of Hexavalent Chromium classified Cr(VI) as a "known human carcinogen by the inhalation route of exposure" based on consistent evidence that inhaled Cr(VI) causes lung cancer in humans and supporting evidence of carcinogenicity in animals (U.S. EPA, 1998c). The same conclusion has since been reached by other authoritative federal and state health agencies and international organizations and the carcinogenicity of Cr(VI) is considered to be well-established for inhalation exposures (TCEQ, 2014; OSHA, 2006; NTP, 2011; NIOSH, 2013; IPCS, 2013; IARC, 2012; CalEPA, 2011).

### 4.4.1 Analysis of Carcinogenicity Data

This section focuses on identifying additional appropriate studies to update the quantitative exposure-response analysis and the derivation of the IUR. More recent epidemiologic studies have been identified in the peer-reviewed literature which include higher quality exposure data, longer follow-up times, larger sample sizes, and more sophisticated analyses than were available in 1998. While the focus of the updated cancer analysis was evaluation of new information and other studies that were not evaluated in the 1998 IRIS assessment, EPA did not exclude studies published prior to 1998. Having judged the evidence of hazard for carcinogenicity of inhaled Cr(VI) to be well-established, EPA focused on studies that could inform estimation of the exposure-response function that could be used to derive an IUR.

#### 4.4.1.1 Identification of Studies for the Derivation of a Cr(VI) Inhalation Unit Risk

##### Study selection

A title and abstract screening of human health studies obtained from the literature searches described in Sections 1.2 and 2.1, and backwards searching using reference lists of screened studies, identified 64 human lung and respiratory cancer references. These studies then underwent full-text screening for exposure-response data that may be informative for derivation of a revised inhalation unit risk. Studies needed to be epidemiological analyses examining quantitative measures of chromium exposure in relation to lung cancer incidence or mortality risk. Studies were excluded if Cr(VI) measurements in air, or convertible equivalents such as CrO_3_, were not presented, or if group-level exposure assignments were based on job title (and not chromium measurements) (see Table D-17 in Appendix D.4). Applying these criteria, there were 22 lung cancer references identified as potentially informative for exposure-response analysis.

All 22 studies were based on occupational cohorts, and many followed the same worksites or worker populations over time. For cohorts with multiple follow-up studies, EPA included only the most recent follow-up, and used the prior studies to obtain information relevant to analysis of data and study evaluation (see Table D-18 in Appendix D.4). Of the 22 studies, five independent cohort studies evaluating Cr(VI) exposure and the risk of lung cancer were obtained after restricting to the most recent cohort follow-up data (see Figure 4-5 and Table 4-20). These were: (1) a chromate facility in Baltimore, MD (Gibb et al., 2000b; 2015; 2020); (2) a chromate facility in Painesville, OH (Proctor et al., 2016); (3) two chromate facilities in Germany (Leverkusen and Uerdingen) (Birk et al., 2006); (4) the IARC multicenter cohort of welders in the European Union (Gerin et al., 1993); and (5) two chromate facilities in the United States (Corpus Christi TX and Castle Hayne NC) (Luippold et al., 2005). A sixth study (AEI, 2002) did not include new data, but was a pooled analysis of the four plants evaluated in (Birk et al., 2006) and (Luippold et al., 2005).

Figure 4-5 Literature screening results for studies containing exposure-response data of Cr(VI) and lung cancer.

The next step was to evaluate the quantitative methods used in each of the analyses. It was preferred that exposure-response analyses were conducted using estimated airborne concentrations of speciated Cr(VI) compounds from which a slope^82^ and its standard error could be obtained. Studies were available that presented results from models using a continuous measure of exposure, so the two that did not (e.g., studies that only presented an overall SMR) were excluded: Luippold et al. (2005) and AEI (2002). An overview of all studies excluded for exposure-response analysis of lung cancer in humans is provided in Appendix D.4 Tables D-17 through D-19. The remaining four studies were then evaluated for risk of bias and sensitivity. Study evaluation included consideration of exposure assessment, outcome ascertainment, population selection, confounding, selective reporting, sensitivity, and data analysis [see Protocol Section 6.2 (see Appendix A) for more details]. Considerable focus was placed on factors that could notably affect the magnitude and direction of the effect estimates, including potential for exposure measurement error, confounding, missing data, and the specific statistical analyses conducted. Summaries of the study evaluations are presented in Table 4-20 along with the overall confidence rating. Details of those evaluations are presented in HAWC (click here (https://hawcprd.epa.gov/summary/visual/100500595/)).

Table 4-20 Summary of included studies considered for the derivation of an inhalation unit risk for Cr(VI) and overall confidence classification.

Click to see interactive data graphic for rating rationales. (https://hawc.epa.gov/summary/visual/assessment/499/CrVI-human-lung-cancer-studies/)

Included | Reference | Study description | Study evaluation
Included | Reference | Study description | Exposure | Outcome | Selection | Confounding | Analysis | Sensitivity | Sel. reporting | Overall confidence
Included | Gibb et al. (2000b); (2015; 2020)^a^ | Occupational cohort (n = 2,354 male workers) in the U.S. exposed 1950-1985 and followed until 2011. | G | G | A | A | G | A | A | High
Included | Proctor et al. (2016) | Occupational cohort (n = 714 male workers) in the U.S. exposed 1940–1972 and followed until 2011. | A | A | G | D | G | A | A | Medium
Included | Birk et al. (2006) | Occupational cohort (n = 901 male workers) in Germany exposed 1958–1998 and followed until 1998. | D | A | A | A | A | D | A | Low
Included | Gerin et al. (1993) | Pooled IARC multicenter occupational cohorts (n = 11,092 male welders) across 135 companies in 9 EU countries exposed during various periods 1946–1986. | D | A | A | D | A | A | A | Low

a Three studies were used to represent the Baltimore, MD cohort, as they had essentially the same worker population.

Three studies describing one cohort were classified as high confidence: Gibb et al. (2000b); (2015; 2020) (the Baltimore MD cohort); and one was classified as medium confidence: Proctor et al. (2016) (the Painesville, OH cohort). The remaining studies were low confidence. The high and medium confidence studies were advanced for further consideration in the derivation of the IUR for Cr(VI). Overviews of the two cohorts and their analyses are provided below followed by an analysis of the preferred characteristics for candidate principal studies for IUR development from occupational cohorts are described in Table 4-21.

##### Overview of the Baltimore, MD cohort

Chromate production at the Baltimore, MD site began in 1845 and ultimately ceased in 1985 (Hayes et al., 1979; Gibb et al., 2000b). The original Baltimore cohort included workers who were newly employed between 1945 and 1974 (Hayes et al., 1979). The current cohort was defined by Gibb et al. (2000b) and excluded most workers who began work before August 1, 1950. This cutoff date coincided with when a new chromite ore mill and roasting plant were constructed, exposure mitigation measures were implemented, and extensive exposure information collection began (Hayes et al., 1979; Gibb et al., 2015). The vital status of 2357 workers were initially followed up through death or the end of 1992 (Gibb et al., 2000b) and then extended through 2011 for 2,354 workers (Gibb et al., 2015) for a total of 91,186 person-years at risk. The mean duration of employment for the 2011 update of the cohort was 3.1 years and the mean number of years of follow-up was 38.9 years. The median duration of employment for the cohort was 0.4 years and the median number of years of follow-up was 39.9 years.

Gibb et al. (2000b) estimated Cr(VI) exposures for each person in each year based on job titles, the time spent in each sampling zone and exposure estimates based on ~70,000 contemporary measurements of Cr(VI) concentration in air during the study period. Samples included short-term air sampling in the workers’ breathing zones from 1950–1961 followed by 24-hour routine measurements taken by 20 air samplers rotated through 154 fixed sites throughout the facility, and personal air sampling beginning in 1977. Exposure estimates were merged with work history data to estimate each workers’ cumulative exposures during employment. All air measurements of Cr(VI) were converted to units of mg CrO_3_/m^3^ as a common basis in Gibb et al. (2000b) because the prevailing regulatory standard was from the metric used by the U.S. Occupational Safety and Health Administration in its past Permissible Exposure Limits for chromic acid and chromates. The mean cumulative exposure^83^ to CrO_3_ reported in Gibb et al. (2015) Table 2 was 0.14 mg/m^3^-years which converts to 72.8 μg/m^3^-years of Cr(VI).^84^ The 25th, 50th, and 75th percentiles were 0.52, 5.2, and 41.6 μg/m^3^-years of Cr(VI). Company medical records provided smoking status at the beginning of employment for 91% of the cohort (Yes/No/Unknown); 74% smoked cigarettes, 16% did not smoke, and smoking status was unknown for 9%. No information on pack-years of smoking or how smoking status may have changed over time was available.

Gibb et al. (2015) reported 217 deaths from lung cancer in this cohort compared with 133 expected deaths based on Maryland vital statistics for a SMR of 1.63 (95% CI: 1.42–1.86). The risk of lung cancer mortality was analyzed using a Cox proportional hazards model with age as the time variable and cumulative exposure as a time-varying covariate. In a model adjusted for smoking and age,^85^ each unit increase in log_10_ cumulative Cr(VI) exposure, lagged by 5 years, was associated with a 1.255-fold (p < 0.001) increase in the hazard ratio.

Gibb et al. (2020) re-analyzed this cohort with the same exposure and outcome data using a Cox proportional hazards model adjusted for smoking and age, but without log-transforming cumulative Cr(VI) exposure. In this analysis, untransformed cumulative Cr(VI) exposure, lagged by 5 years, was associated with a 1.64-fold (95% CI: 1.30, 2.04) increase in the hazard ratio. Gibb et al. (2020) also reported analyses of the untransformed cumulative Cr(VI) exposure using a conditional Poisson regression approach (Richardson and Langholz, 2012) to estimate the relative risk per unit of cumulative exposure (controlling for age and smoking) showing that cumulative Cr(VI) exposure, lagged by 15 years, was associated with a 1.82-fold (95% CI: 1.35, 2.45) increase in the hazard ratio.

##### Overview of the Painesville, OH cohort

The Painesville, OH chromate production plant was in operation from 1931–1972, with major renovations occurring in 1949–1950 and 1962–1964 to mitigate exposure and modernize plant operations (Proctor et al., 2004). Previous analyses of the Painesville plant relied on indirect measures of Cr(VI) in air, using measures of air total chromium and soluble/insoluble chromium dust measurements, and only studied workers employed prior to 1940 (Mancuso, 1975, 1997). The current cohort was defined by Proctor et al. (2016) to include workers employed after December 31, 1939. The vital statistics of 714 workers were followed up through death or the end of 2011 for a total of 24,535 person-years at risk. The mean duration of employment for the cohort was not explicitly reported but falls within the interval of 5 to 9 years (see Table 1 in Proctor et al. (2016) and the mean number of years of follow-up was 34.4 years.

The Proctor et al. (2004); (2016) studies obtained 800 measurements of airborne Cr(VI) from 23 historical industrial hygiene surveys for workers employed from 1940–1972. Using historical records of worker job histories over time and industrial hygiene data (which included Cr(VI) measurements), a job-exposure matrix (JEM) was constructed (Proctor et al., 2004). Usable data were available for 1943, 1945, 1948, 1957, and 1959–1971 (excluding 1962). Exposure estimates were merged with work history data to estimate each workers’ cumulative exposures during employment. All Cr(VI) cumulative exposure estimates were reported in mg/m^3^-years. The mean cumulative exposure to Cr(VI) was 1.1 mg/m^3^-years (Proctor et al., 2016) which converts to 1.1 × 10^3^ μg/m^3^-years with a range of 0.2 × 10^3^ μg/m^3^-years to 22.1 × 10^3^ μg/m^3^-years. Employee records provided smoking status for 29% of the cohort (Yes/No/Unknown); of those, 22% smoked cigarettes, 7% did not smoke, and smoking status was unknown for 72%. No information on pack-years of smoking or how smoking status may have changed over time was available.

Proctor et al. (2016) reported 77 deaths from lung cancer in this cohort which yielded a SMR of 1.86 (95% CI: 1.45–2.28) compared with lung cancer mortality in Ohio and a SMR of 2.05 (95% CI: 1.59–2.50) compared with the U.S. population. Proctor et al. (2016) fit several models within the cohort and concluded that the linear Cox model with age as the time variable and controlling for smoking and age at hire had the best fit and reported a hazard ratio of 1.19 per mg/m^3^-years increase in Cr(VI) exposure based on a regression coefficient of 0.17 per mg/m^3^-years (95% CI: 1.11–1.27; p = 0.0006).

Table 4-21 Details of rationale for selecting a principal study on Cr(VI) for IUR derivation

Attribute | Preferred characteristics for candidate principal studies for the Cr(VI) IUR | Baltimore, MD Cohort | Painesville, OH Cohort
Study design characteristics | Sufficient follow-up time for outcomes to develop (this can depend on the health outcome being addressed).; Study size and participation rates that are adequate to detect and quantify health outcomes being studied (without influential biases in study population selection) are preferred.; Use of a study design or analytic approach that adequately addresses the relevant sources of potential confounding, including age, sex, and exposures to other risk factors for the outcome of interest. | Total person-time at risk: 91,186 person-yr; Size of cohort: 2,354 workers; Mean follow-up time: 38.7 yr; Confounding potential: Controlled for age and smoking; no mesothelioma deaths; Effect modification potential: No known asbestos exposure and no mesothelioma deaths. | Total person-time at risk: 24,535 person-yr; Size of cohort: 714 workers; Mean follow-up time: 34.4 yr; Confounding potential: Controlled for age and smoking; 6 mesothelioma deaths; Effect modification potential: asbestos exposure is strongly indicated with 6 mesothelioma deaths.
Relevance of exposure paradigm | Studies of chronic duration are preferred over studies of shorter exposure duration because they are most relevant to environmental exposure scenarios (potentially including both continuous exposure from ambient conditions and episodic activity-related exposures).; When available studies observe effects across different ranges of exposures, studies that include relatively low exposure intensities that may represent conditions more similar to environmental exposures are preferred as there may be less uncertainty in extrapolation of those results to lower exposure levels. | Chronic duration; Mean exposure Cr(VI): 72.8 μg/m^3^-yr; The 25th, 50th, and 75th% were 0.52, 5.2, and 41.6 μg/m^3^-yr | Chronic duration; Mean exposure Cr(VI): 1.1 × 10^3^ μg/m^3^-yr; Range from 0.2 μg/m^3^-years to 22.1 × 10^3^ μg/m^3^-yr
Measurement of exposure | Emphasis is placed on the specificity of exposure assessment in time and place with a preference for greater detail where possible. Exposure measurements that are site and task specific provide generally preferred exposure information. Where available, individual-level measurements are generally preferred. Measurement techniques that are more specific to the agent of concern are preferred over less specific analytical methods. Better characterization of airborne concentrations is preferred.; Stronger studies will often be based upon knowledge of individual work histories (job titles/tasks with consideration of changes over time); however, appropriate group-based exposure estimates may also be relevant.; Exposure reconstruction and estimating exposures based on air sampling from other time periods and/or operations are less preferred methods of exposure estimation. | ~70,000 measurements during 1950–1974.; Early samples were short-term air samples in the workers’ breathing zones, later 24-hr samples from 154 fixed sites, and full-shift personal air sampling began in 1977.; Sampling records for 9 yr could not be located (1950–1956, 1960–1961) and those values were imputed based on existing data to model those job-specific exposure values.; Individual work histories matched to job-specific exposure estimates based on sampling measurements. | 800 measurements during 1940–1972.; No personal samples.; Uncertainty in short-term workers’ exposures: Proctor et al. (2004) “company records lacked sufficient information on these individuals to reconstruct their work histories.”; Individual work histories matched to job-specific exposure estimates based on sampling measurements.
Measurement of covariates | Studies that considered the potential effects of confounding by relevant covariates are preferred over those without such consideration—unless confounding is not a major concern. | Age is well measured.; Smoking status was identified for 93% of the cohort. | Age is well measured.; Smoking status was identified for 28% of the cohort.
Measurement of effect(s) | Cancer incidence data are generally preferred over cancer mortality data (U.S. EPA, 2005a). In the absence of cancer incidence data, cancer mortality data are appropriate with preference for cause of death classified using international classification disease (ICD) codes at time of death. | Lung cancer data were obtained from death certificates.; 217 lung cancer cases.; No deaths from mesothelioma and no evidence of outcome misclassification. | Lung cancer data were obtained from death certificates.; 77 lung cancer cases.; 3 deaths from mesothelioma (of 6 total) were initially classified as lung cancer deaths
Analysis methodology | Studies conducting and reporting regression results of within cohort comparisons and those with β and SE(β) are preferred over standardized mortality ratio (SMR) results. Occasionally studies reporting standardized rate ratio (SRR) or SMR results with sufficient specificity by exposure category may allow for post hoc estimation of β and SE(β)—although if the lowest exposure category is defined by the lowest quantile/category of exposure, such estimates may be biased toward the null. | Analyses included multiple model forms (types of regression) with multiple parameterizations of covariates and lags for exposure. | Analyses included multiple model forms (types of regression) with multiple parameterizations of covariates and lags for exposure.

Table 4-21 summarizes key considerations related to study attributes that were considered in the rationale for identifying the principal cohort. The Baltimore, MD cohort was (1) larger than the Painesville cohort, (2) had longer follow-up time, (3) had more deaths from lung cancer, (4) had no deaths from mesothelioma, despite having 66,651 additional years of person-time at risk than in the Painesville cohort, suggesting lower potential for confounding by asbestos exposure, (5) had more than an order of magnitude lower average exposures which can be more relevant to estimating effects at lower exposures and requires less extrapolation, (6) had more air samples to estimate exposures, and (7) had more complete data on smoking. EPA selected the Baltimore, MD cohort as the basis for deriving the IUR.

### 4.4.2 Dose-Response Analysis–Adjustments and Extrapolations Methods

The first step toward deriving an inhalation unit risk for lung cancer was to identify candidate effect estimates (i.e., beta coefficients from the regression analyses) from studies of the principal cohort. Once the lung cancer effect estimates have been obtained, they are adjusted for differences in air volumes between workers and other populations due to exposure frequency and breathing rates. Conversions between occupational Cr(VI) exposures and continuous environmental exposures were made to account for differences in the number of days exposed per year, and in the amount of air inhaled per day. Those adjusted values can be applied to the U.S. population as a whole in EPA life-table analyses. These life-table analyses allow for the estimation of an exposure concentration associated with a specific extra risk of cancer incidence caused by inhalation of Cr(VI); the specific extra risk is called the benchmark response (BMR) and a value of 1% is standard for cancer outcomes in people. Those exposure concentrations serve as points of departure (POD) from which IURs can be extrapolated. Non-occupational exposure adjustment and methods applied for the life-table analysis are described in detail in Section 4.4.3.

Because a mutagenic mode of action for Cr(VI) carcinogenicity (see Section 3.2.3) is “sufficiently supported in (laboratory) animals” and “relevant to humans,” EPA used a linear low dose extrapolation from the POD in accordance with Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a).

#### 4.4.2.1 Cancer Risk Models for Cr(VI) Inhalation Exposures

A cancer risk model predicts the probability of cancer in an individual with a specified history of exposure to a cancer-causing agent. In the case of inhalation exposure to Cr(VI), the lung cancer effects are of chief concern, and workers’ individual cumulative exposure to Cr(VI) are used to predict cancer risk. Different types of regression analyses were used to model the lung cancer effect of Cr(VI) in the Baltimore, MD cohort. The model forms are described below.

The Cox proportional hazards model (Cox, 1972) is one of the most commonly used statistical models for the epidemiologic analysis of survival and mortality in cohort studies with extensive follow-up, including studies of the Baltimore, MD cohort (Gibb et al., 2000b; 2015; 2020). The Cox proportional hazards model assumes that a function of covariates (e.g., exposures) result in hazard functions that are a constant proportion of the baseline hazard function in unexposed individuals over some timescale, typically calendar time or age (e.g., the background age-specific rates of lung cancer in the population). One of the strengths of this model is that knowledge of the baseline hazard function is not necessary, and no particular shape is assumed for the baseline hazard; rather, it is estimated nonparametrically.

Another methodology used to analyze the Baltimore, MD cohort (Gibb et al., 2020) was the conditional Poisson regression approach proposed by Richardson and Langholz (R&L) to estimate the relative risk per unit of cumulative exposure (Richardson and Langholz, 2012). The R&L approach maximizes a conditional likelihood expression that allows for covariates like age and smoking to be included in the model but avoids estimation of all the stratum-specific parameters by treating them as nuisance terms. This property is made possible by separating and then cancelling the nuisance terms in the likelihood function. Thus, the R&L approach models the effects of age and smoking when estimating the effect of Cr(VI) but does not yield the specific effect estimates for age and smoking.

#### 4.4.2.2 Cancer Risk Parameters

The Cox regression results from the Baltimore, MD cohort are shown in Table 4-22.

Table 4-22 Results of Cox proportional hazards modeling of cumulative chromium exposure (mg CrO_3_/m^3^-years) by different lag periods (age and smoking are included in model). Table adapted from Table 1 of Gibb et al. (2020).

Lag period (yr) | β per mg CrO_3_/m^3^-yr | SE(β) | Hazard ratio Exp(β) | 95% CI (β) | −2 log(L)
0 | 0.4712 | 0.1133 | 1.60 | 1.28–2.00 | 2830.23
5 | 0.4868 | 0.1145 | 1.63 | 1.30–2.04 | 2829.80
10 | 0.4939 | 0.1197 | 1.64 | 1.30–2.07 | 2830.52
15 | 0.4812 | 0.1333 | 1.62 | 1.25–2.10 | 2833.03

Note: 1 mg CrO_3_ = 0.520 mg Cr(VI); CrO_3_/m^3^-year = (CrO_3_/m^3^)(year).

The measure of fit (−2 Log(L)) of the Cox proportional hazards models of the lung cancer risk adjusted for age and smoking were very similar for all lag periods, although the fit for the 5-year lag was slightly better than for the other lags—although not statistically better. The rationale for the lag period is that there is often a latency period for cancer beginning with the initial incidence of cancer and extending to the time of cancer mortality. In this conceptual model, the exposures that are experienced by the individual after cancer has begun are no longer expected to cause lung cancer, and thus those exposures may not be etiologically relevant. Here the results show little difference in effect size across the different lag times. This is likely due to the fact that exposures ceased in 1982 and follow-up continued until 2011 so there was little difference in lagged and unlagged exposures. Section 4.4.5 provides a sensitivity analysis across the different lag lengths.

The lung cancer effect estimate for the 5-year lag in Table 4-22 above (Gibb et al., 2020) is in units of per mg CrO_3_/m^3^-year and was converted to unit of per μg Cr(VI)/m^3^-year as follows:

1 m g C r O_3_ / m^3^ -year • [0.52 m g C r ( V I ) / m g C r O_3_] • [ 1000 μ g / m g ] = 520 μ g C r ( V I ) / m^3^ -year 5-year lag β_C r ( V I )_ = 0.4868 per m g C r O_3_ / m^3^ -year = 0.4868 / (1 m g C r O_3_ / m^3^ -year)

= 0.4868 / (520 μ g C r ( V I ) / m^3^ -year) = 9.362 × 10^- 4^ per μ g C r ( V I ) / m^3^ -year

The inhalation unit risk is derived from the one-sided 95th% upper bound of β. Gibb et al. (2020) reported a two-sided 95% confidence interval as is the standard practice in the epidemiologic literature (i.e., from the 2.5th% to the 97.5th% bounds). EPA estimated the one-sided 95th% upper bound (UB) of β by assuming the distribution of β was normally distributed (which is appropriate for the Cox Proportional Hazards model) as follows:

One-sided 95 th % UB of β = β + 1.645 ( s e ( β ) )

= 0.4868 per m g C r O_3_ / m^3^ -year + 1.645 • (0.1145 per m g C r O_3_ / m^3^ -year)

= 0.6752 per m g C r O_3_ / m^3^ -year = (0.6752 per m g C r O_3_ / m^3^ -year) / (520 μ g C r ( V I ) / m^3^ -year) = 1.298 × 10^- 3^ per μ g C r ( V I ) / m^3^

This one-sided 95th% upper bound of β from the Cox Proportional Hazards analysis in Gibb et al. (2020) will be used to derive an estimate of the IUR using a life-table analysis. R&L regression results from the Baltimore, MD cohort are shown in Table 4-23.

Table 4-23 Results for relative exponential exposure-response (R&L) model adjusted for age and smoking. Table adapted from Table 2 of Gibb et al. (2020).

# Age groups^a^ | Lag period (y) | β | SE(β) | RR = exp(β) | 95% CI(β) | −2 log(L)
1 | 0 | 0.454 | 0.098 | 1.57 | 1.30–1.91 | 9,283.51
1 | 5 | 0.454 | 0.098 | 1.57 | 1.30–1.91 | 9,283.62
1 | 10 | 0.451 | 0.101 | 1.55 | 1.29–1.91 | 9,286.50
1 | 15 | 0.414 | 0.108 | 1.51 | 1.22–1.87 | 9,291.89
2 | 0 | 0.454 | 0.098 | 1.57 | 1.30–1.91 | 9,283.50
2 | 5 | 0.461 | 0.098 | 1.59 | 1.31–1.92 | 9,282.79
2 | 10 | 0.463 | 0.100 | 1.59 | 1.31–1.93 | 9,284.08
2 | 15 | 0.474 | 0.107 | 1.60 | 1.30–1.98 | 9,286.46
3 | 0 | 0.915 | 0.047 | 2.50 | 2.28–2.74 | 8,854.75
3 | 5 | 0.933 | 0.048 | 2.59 | 2.31–2.79 | 8,846.57
3 | 10 | 0.982 | 0.050 | 2.67 | 2.42–2.94 | 8,845.78
3 | 15 | 1.088 | 0.056 | 2.97 | 2.66–3.31 | 8,848.71
4 | 0 | 0.506 | 0.133 | 1.66 | 1.28–2.15 | 4,327.08
4 | 5 | 0.522 | 0.133 | 1.69 | 1.30–2.19 | 4,326.07
4 | 10 | 0.548 | 0.139 | 1.73 | 1.32–2.27 | 4,325.97
4 | 15 | 0.599 | 0.152 | 1.82 | 1.35–2.45 | 4,325.95
5 | 0 | 1.179 | 0.036 | 3.25 | 3.03–3.49 | 8,153.85
5 | 5 | 1.246 | 0.036 | 3.48 | 3.24–3.73 | 8,091.17
5 | 10 | 1.387 | 0.040 | 4.00 | 3.70–4.33 | 8,035.39
5 | 15 | 1.559 | 0.044 | 4.75 | 4.36–5.18 | 8,030.41
6 | 0 | 1.142 | 0.036 | 3.13 | 2.92–3.36 | 8,253.33
6 | 5 | 1.164 | 0.036 | 3.20 | 2.98–3.44 | 8,235.51
6 | 10 | 1.200 | 0.038 | 3.39 | 3.08–3.58 | 8,238.56
6 | 15 | 1.375 | 0.043 | 3.95 | 3.64–4.30 | 8,223.38

Note: 1 mg CrO_3_ = 0.520 mg Cr(VI).

a One age group (all ages, 15–96); two age groups (≥15 to 65 and ≥65); three age groups (ages ≥15 to 60, ≥60 to ≥70); four age groups (≥15 to 60, ≥60 to 65, ≥65 to 75, and ≥75); five age groups (ages ≥15 to 60, ≥60 to 65, ≥65 to 70, ≥70 to 75, and ≥75);six age groups (ages ≥15 to 55, ≥55 to 60, ≥60 to 65, ≥65 to 70, ≥70 to 75, and ≥75).

The R&L analysis based on four age groups fit the Baltimore, MD cohort better than the analyses based on other numbers of age groups as evidenced by the lower fit statistics, and within the 4-age group analysis, the fits were very similar for all lag periods, although the fit for the 15-year lag was slightly better than for the other lags—although not statistically better. Section 4.4.5 provides a sensitivity analysis across the different lag lengths.

The lung cancer effect estimate for the 15-year lag in Table 2 from Gibb et al. (2020) is 0.599 per mg CrO_3_/m^3^-year and was converted to unit of per μg Cr(VI)/m^3^-year as follows:

1 m g C r O_3_ / m^3^ -year ∙ [0.52 m g C r ( V I ) / m g C r O_3_] • [ 1000 μ g / m g ] = 520 μ g C r ( V I ) / m^3^ -year 5 -year lag β_C r ( V I )_ = 0.599 per m g C r O_3_ / m^3^ -year = 0.599 / (1 m g C r O_3_ / m^3^ -year)

= 0.599 / (520 μ g C r ( V I ) / m^3^ - year ) = 1.152 × 10^- 3^ per μ g C r ( V I ) / m^3^ - year

One-sided 95th % UB of β = β + 1.645 ( se ( β ) )

= 0.599 per m g C r O_3_ / m^3^ - year + 1.645 • (0.152 per m g C r O_3_ / m^3^ - year ) = 0.849 per m g C r O_3_ / m^3^ -year = (0.849 per m g C r O_3_ / m^3^ -year ) / (520 μ g C r ( V I ) / m^3^) = 1.633 × 10^- 3^ per μ g C r ( V I ) / m^3^

This one-sided 95th% upper bound of β from the R&L analysis in Gibb et al. (2020) will be used to derive an estimate of the IUR using a life-table analysis.

### 4.4.3 Inhalation Unit Risk Derivation

#### 4.4.3.1 Life-Table Analysis to Derive an IUR

The β coefficients (slopes) for lung cancer risks attributable to cumulative exposures to Cr(VI) from the Gibb et al. (2020) are used in life-table analyses to predict the risk of cancer as a result of the exposure over a lifetime. The life-table analysis divides a lifetime into small age-specific intervals and sums the risks of lung cancer incidence in each age group in the presence and absence of Cr(VI) exposure. This is done to assess the age-specific risk of lung cancer incidence while accounting for competing causes of death. The lung cancer risk in a particular year of life is conditional on the assumption that the individual is alive, and at risk of incident lung cancer, at the start of the year for each age-specific interval. Consequently, the risk of a Cr(VI)-related lung cancer within a specified year of life is calculated as a function of (1) the probability of being alive at the start of the year, (2) the background probability of getting lung cancer, and (3) the increased risk of getting lung cancer from Cr(VI) exposure within the specified year. The lifetime risk is then the sum of all the yearly risks. This procedure is performed to calculate the lifetime risk both for an unexposed individual (R0) and for an individual with exposure to Cr(VI) (Rx).

“Extra risk” for lung cancer is a calculation of risk which adjusts for background incidence rates of lung cancer, by estimating risk at a specified exposure level and is calculated as follows (U.S. EPA, 2012a):

Extra Risk = ( R x - R 0 ) / ( 1 - R 0 )

The inhalation unit risk (IUR) is the risk of incident lung cancer per unit concentration (μg/m^3^) in inhaled air. The unit risk is calculated by using life-table analysis to find the exposure concentration (EC) that yields a 1% (0.01) extra risk of lung cancer. The 1% value is referred to as the Benchmark Response (BMR). This 1% value is used because lung cancer is a severe adverse effect and 1% also represents a lung cancer response level that is near the low end of the observable range (U.S. EPA, 2012a). This is also consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012b), which notes that a BMR of 1% is typically used for epidemiological data since higher values may involve upward extrapolation.

Because a mutagenic MOA for Cr(VI) carcinogenicity (see Section 3.2.3) is “sufficiently supported in (laboratory) animals” and “relevant to humans,” EPA used a linear low dose extrapolation from the POD in accordance with the Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a). Given the EC associated with a 1% extra risk (EC_01_), the unit risk is the slope of a linear exposure-response line from the origin through the EC_01_:

Unit Risk = 0.01 / E C_01_

A unit risk value may be calculated based on both the best estimate (β) and the one-sided 95% upper confidence bound (UB) on the best estimate. The value based on the one-sided upper 95% confidence bound is normally used for decision-making, since it corresponds to a one-sided lower 5% confidence bound (LB) on the exposure level yielding 1% extra risk (LEC_01_).

I U R = 0.01 / L E C_01_

Life-table calculations require as input the all-cause mortality rate estimates and lung cancer incidence rate estimates for the general U.S. population in each year of life. The all-cause mortality data were obtained from the National Vital Statistics Report Vol 68 No 7 Table 1 (Arias et al., 2017), which provides data from the U.S. population in 2017. Lung cancer incidence rate data were obtained by downloading 2017 data for malignant neoplasms of bronchus and lung (ICD-10 C33-C34) from CDC WONDER.^86^ Because cause-specific rates were given for 5-year intervals, the cause-specific rate for each 5-year interval was applied to each age within the interval.

The detailed equations for calculating lifetime excess cancer risk for a specified exposure concentration in the presence of competing risks are based on the approach used by (NRC, 1988) for evaluating lung cancer risks from radon. The equations are detailed in Appendix E. The SAS code for lung cancer life-table analysis was provided to EPA by NIOSH^87^ and was adapted for use by (1) entering the data noted above; (2) adding adjustment factors to account for differences between occupational exposures and non-occupational exposure; (3) adding an equation to compute extra risk; and (4) adding a macro to solve for the EC_01_ or the LEC_01_. The SAS codes for performing the lung cancer life-table calculations are provided in Appendix E.

The adjustment factors to account for differences between occupational exposures and nonoccupational exposure follow EPA guidance (U.S. EPA, 2009) that acknowledges there are differences in breathing rates between workers (10 m^3^ per 8-hour day) and non-workers (20 m^3^ per 24-hour day) and that workers are exposed 240 days per year while non-workers are exposed 365 days per year (U.S. EPA, 2011d, 2012d, 2014e, 2016b). Thus, a worker is assumed to inhale 2,400 m^3^ of workplace air per year while a non-worker is assumed to inhale 7,300 m^3^ of air per year. Since the effect estimates for Cr(VI) effects on lung cancer risks are in terms of ‘per occupational year’, the life-table procedure adjusts for the differences in air volume breathed per year to represent non-occupational exposures.

#### 4.4.3.2 Summary of Lifetime Unit Risk Estimates—Not Accounting for Assumed Increased Early-Life Susceptibility

The derivation of the unit risk—not accounting for assumed increased early-life susceptibility—is based upon the two main regression modeling results in Gibb et al. (2020): (1) the Cox Proportional Hazard model with exposure lagged by 5 years, and (2) the R&L model with four age groups and exposure lagged by 15 years (see Table 4-24). Note that this estimate of the unit risk is based on the assumption that the relative risks or hazard ratios are independent of age.

Table 4-24 Calculation of lifetime cancer unit risk estimate not accounting for assumed increased early-life susceptibility

Source | Table in original publication | β (slope) per mg CrO_3_/m^3^ | | β (slope) [μg Cr(VI)/m^3^]^−1^ | | Exposure concentration associated with BMR (1% extra risk) [μg Cr VI)/m^3^]^−1^ | | Lifetime unit risk [μg Cr(VI)/m^3^]^−1^
Source | Table in original publication | MLE | 95% UB | MLE | 95% UB | EC_01_ MLE | LEC_01_ 5% LB | MLE | 95% UB
Gibb et al. (2020) Cox PH Model | Table 1 5-yr lag | 0.487 | 0.675 | 9.36 × 10^−4^ | 1.30 × 10^−3^ | 1.25 | 0.899 | 8.02 × 10^−3^ | 1.11 × 10^−2^
Gibb et al. (2020) R&L Model | Table 2 4 age groups 15-yr lag | 0.599 | 0.849 | 1.15 × 10^−3^ | 1.63 × 10^−3^ | 1.35 | 0.952 | 7.41 × 10^−3^ | 1.05 × 10^−2^

The results from the Cox model yielded an estimate of the lifetime unit risk of 1.11 × 10^−2^ per μg Cr(VI)/m^3^ while the results from the R&L model yielded an estimate of the lifetime unit risk of 1.05 × 10^−2^ per μg Cr(VI)/m^3^. These two estimates are very close to each other and thus mutually support one another. EPA advanced the estimate of the lifetime unit risk derived from the Cox proportional hazards models with an exposure lag of 5 years for the following reasons: (1) the Cox proportional hazards model is a well established method for epidemiological analyses that is commonly used in cohort studies, and (2) the results from this type of model have been used as the basis for EPA IRIS IUR derivations for lung cancer (U.S. EPA, 2014e). In the absence of evidence of early-life susceptibility, the lifetime unit risk for lung cancer caused by inhalation exposure to Cr(VI) is considered to be best estimated as 1.11 × 10^−2^ per μg Cr(VI)/m^3^, which rounds to 1.1 × 10^−2^ per μg Cr(VI)/m^3^.

Because a mutagenic mode of action for Cr(VI) carcinogenicity (see Section 3.2.3) is “sufficiently supported in (laboratory) animals” and “relevant to humans,” and as there are no chemical-specific data to evaluate the differences between adults and children, increased early-life susceptibility should be assumed. If there is early-life exposure, age-dependent adjustment factors (ADAFs) are applied, as appropriate, in accordance with the EPA’s Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b). See Section 4.4.4 below for more details on the application of ADAFs.

### 4.4.4 Application of Age-Dependent Adjustment Factors

The derivation of the IUR when increased early-life susceptibility should be assumed is based on the same main Cox proportional hazards regression modeling results with exposure lagged by 5 years (Gibb et al., 2020). The process for deriving an IUR when increased early-life susceptibility should be assumed involves an initial estimation of a unit risk based only on adult-only exposures (U.S. EPA, 2016b), followed by the application of age-dependent adjustment factors to age-specific risks for children under age 16 years, and a summary of risks across all ages weighted by the age-dependent adjustment factors. This is accomplished with several steps.

- The first step is to apply the effect estimate (i.e., the MLE β) from the Baltimore, MD cohort and the 95% UB in a lifetable initiating exposures at 16 years of age—instead of at birth. This process estimates the unit risks for the 54-year period between age 16 years and age 70 years (IRIS’ assumption of a lifetime).
- The values of the EC01 and LEC01 are derived in the same way using the life-table procedure.
- These EC01 and LEC01 values are then divided into the benchmark response of 1% to compute the ‘adult-exposure-only’ unit risk estimates.
- The “adult-exposure-only” unit risk estimates are multiplied by 70/54 to rescale the 54-year adult period to 70 years. This yields the ‘adult-based’ lifetime unit risk.
- The last step is to apply the ADAFs which adjust the ‘adult-based’ lifetime age-specific unit risk for children ages less than 2 years upwards by 10-fold during those years of life, and the unit risk for children ages 2–15 upwards by 3-fold during those years of life, and then applies the unadjusted ‘adult-based’ lifetime unit risk for people aged 16–70 during those years of life. The weighted sum of these three partial unit risks is the ADAF-adjusted lifetime IUR.

Table 4-25 Calculation of total cancer unit risk estimate from adult-only exposure

Source | β (Slope) per μg Cr(VI)/m^3^ | | Exposure concentration associated with BMR (1% Extra Risk) Starting exposure at age 16 yr [μg Cr VI)/m^3^] | | Adult-exposure-only unit risk [μg Cr(VI)/m^3^]^−1 ^(54 yr) | | Adult-based unit risk [μg Cr(VI)/m^3^]^−1^ (70 yr)
Source | MLE | 95% UB | EC_01_(16+) MLE | LEC_01_(16+) 5% LB | MLE | 95% UB | MLE | 95% UB
Gibb et al. (2020) Cox PH Model 5-yr lag | 9.36 × 10^−4^ | 1.30 × 10^−3^ | 1.64 | 1.18 | 6.12 × 10^−3^ | 8.48 × 10^−3^ | 7.93 × 10^−3^ | 1.11 × 10^−2^

The results from the Cox model (see Table 4-25, above) yielded an estimate of the ‘adult-based’ unit risk of 1.1 × 10^−2^ (rounded from 1.11 × 10^−2^) [μg Cr(VI)/m^3^]^−1^. Application of the ADAFs to the ‘adult-based’ (rescaled as discussed above) unit risk estimate for Cr(VI) for a lifetime inhalation exposure scenario is presented below in Table 4-26. The unit risk for each age group is the product of the values for the ADAF, the adult-based unit risk, and the duration adjustment in columns 2–4 ([e.g., 10 × (1.1 × 10^−2^ [μg Cr(VI)/m^3^]^−1^) × 2/70 = 3.1 × 10^−3^ [μg Cr(VI)/m^3^]^−1^), and the total unit risk is the sum of the partial unit risks. This lifetime inhalation unit risk estimate is adjusted for potential increased early-life susceptibility, assuming a 70-year lifetime.

Table 4-26 Total cancer unit risk for a constant Cr(VI) exposure from ages 0–70 years, adjusted for potential increased early-life susceptibility

Age group | ADAF | Adult-based unit risk [μg Cr(VI)/m^3^]^−1^ | Duration adjustment | Unit risk [μg Cr(VI)/m^3^]^−1^
0–<2 yr | 10 | 1.1 × 10^−2^ | 2 yr/70 yr | 3.1 × 10^−3^
2–<16 yr | 3 | 1.1 × 10^−2^ | 14 yr/70 yr | 6.6 × 10^−3^
≥16 yr | 1 | 1.1 × 10^−2^ | 54 yr/70 yr | 8.5 × 10^−3^
| | | Total Lifetime Unit Risk: | 1.8 × 10^−2^

If calculating the cancer risk for a 30-year exposure to a constant average concentration of 0.01 μg Cr(VI)/m^3^ from ages 0 to 30 years, the duration adjustments would be 2/70, 14/70, and 14/70, and the partial risks would be (10 × 0.011 [μg Cr(VI)/m^3^]^−1^ × 0.01 [μg Cr(VI)/m^3^] × 2/70 = 3.1 × 10^−5^), (3 × 0.011 [μg Cr(VI)/m^3^]^−1^ × 0.01 [μg Cr(VI)/m^3^] × 14/70 = 6.6 × 10^−5^), and (1 × 0.011 [μg Cr(VI)/m^3^]^−1^ × 0.01 [μg Cr(VI)/m^3^] × 14/70 = 2.2 × 10^−5^), resulting in a total risk estimate of 1.2 × 10^−4^.

If calculating the cancer risk for a 30-year exposure to a constant average concentration of 0.01 μg Cr(VI)/m^3^ from ages 20 to 50 years, the duration adjustments would be 0/70, 0/70, and 30/70, and the partial risks would be 0, 0, and (1 × 0.011 [μg Cr(VI)/m^3^]^−1^ × 0.01 [μg Cr(VI)/m^3^] × 30/70 = 4.7 × 10^−5^), resulting in a total risk estimate of 4.7 × 10^−5^.

### 4.4.5 Uncertainties in the Derivation of the Inhalation Unit Risk

Several potential sources of uncertainty were identified in the derivation of the Cr(VI) inhalation unit risks. As discussed below, these were not found to be major influences in this evaluation—including two potential sources of uncertainties generally associated with larger uncertainty (model uncertainty and low dose extrapolations). Uncertainties related to genetics, physiological differences, and particle deposition have been discussed previously in this assessment (see Sections 3.1.1.2 and 3.3.1), and the inhalation unit risk represents an upper bound on the average risk in a population (U.S. EPA, 2005a).

Sources of uncertainty in this assessment are outlined below.

#### 4.4.5.1 Uncertainty in Exposure Assessment

Routine air sampling was initiated after construction of the new Baltimore, MD facility in 1950 and followed written documentation specifying strategies for air sampling. Sampling was intended to represent the “typical/usual exposures” to workers (Gibb et al., 2000b). Table 4-27 below details the sampling regimen over time. In constructing the job-exposure-matrix to assign individual exposure for each worker, Gibb et al. (2000b) relied on approximately 70,000 measurements across the study period. While the sampling regimes changed over time and can reasonably be expected to have improved in quantity and specificity, the samples were collected methodically and used the same analytical method for assessing Cr(VI) concentration in dust over the study period (Gibb et al., 2000b).

These exposure estimates were used to construct a job-exposure-matrix (JEM) for each of the 114 job titles in each of the 36 years of the study period. According to Gibb et al. (2000b), the JEM was “virtually complete” for the later years (1971–1985) and “fairly complete” for the early years from 1950–1956 and 1960–1961. While the sampling records for 9 years could not be located, those values were imputed based on existing data to model those job-specific exposure values. EPA considered uncertainty to be low for the 24 out of 36 years when sampling records were available and low-to-medium for the missing years that were bookended by actual sampling values. As exposures may reasonably be assumed to have decreased over the study period as industrial hygiene practices improved, the interpolation between higher and lower exposure periods was likely to have captured those interim exposure concentrations.

Table 4-27 Overview of air sampling program for the Baltimore cohort evaluated by (Gibb et al., 2000b; 2015)

Exposure measurement system | Years implemented | Frequency and duration
Airborne dust via high-volume air sampling pumps and impingers, with sampling wand held in worker breathing zone. | 1950–1961 | Short-term samples (tens of min).
24-hr routine measurements (fixed-site monitors) using 20 tape air samplers (Research Appliance Co., Allison Park, PA). Observation of how much workers spent in the vicinity of each of these monitors. | Mid-1960s–1979 | 24 1-hr samples. Samplers rotated through 154 fixed sites representing exposure zones.
24-hr routine measurements (fixed-site monitors) using 20 tape air samplers (Research Appliance Co., Allison Park, PA). Observation of how much workers spent in the vicinity of each of these monitors. | 1979–1985 | After 1979, frequency reduced to 8 3-hr samples, and number of fixed sites reduced to 27.
Routine personal sample collection using NIOSH standard method P and CAM 169 NIOSH (1972). | 1977–1985 | Full-shift sampling.

#### 4.4.5.2 Uncertainty in the Exposure Metric

Gibb et al. (2000b) fit multiple models of lung cancer risks using untransformed and transformed cumulative exposure to Cr(VI) with log base-10 transformed Cr(VI) providing the better overall model fit. Gibb et al. (2015) also reported updated lung cancer results based on log base-10 of cumulative exposure to Cr(VI). While log transformation of concentration-based cumulative exposure is commonplace in epidemiological analyses because those concentrations are often log-normally distributed, risk calculation based on log-transformed exposure suffer from exposure-response irregularities such as zero risk whenever the exposure has a numerical value of one (in any units) [i.e., log10(1) = 0 or ln(1) = 0], and when risks are extrapolated below one unit of exposure, the sign of the risk estimate flips from positive to negative such that lower exposure appears to be health protective as an artifact of the transformation. For the purpose of estimating an IUR, exposure-response results in terms of untransformed cumulative exposures to Cr(VI) can be more useful than log-transformed exposures. Gibb et al. (2020) reported risks of lung cancer associated with untransformed cumulative Cr(VI). While a transformed exposure may provide a better overall model across the entire range of exposures in a study, as in the case of Gibb et al. (2020), those model results did not meet the needs for estimating an IUR based on a POD in the low exposure range, and thus EPA selected the results from the models based on untransformed cumulative Cr(VI)—even if there is some uncertainty concerning the relative fits of different exposure metrics.

The two candidate IURs are based on the same cohort that was the most highly rated and preferred, based on the majority of additional considerations for exposure-response, although there are some aspects of the specific modeling details that were further considered in order to judge their potential impact on the IUR. Specifically, in the exposure lags and the number of age groups that yielded the better overall fits, often the fit differences were small enough so as to be essentially equal in fit. Three additional sets of candidate unit risks were derived to show the differences in those values had those combinations been selected instead and to allow for comparison between the two candidate IURs on a common basis of exposure lag length (see Table 4-28).

Table 4-28 Variation in unit risks among the Cox Proportional Hazards model results by lag length

Cox proportional hazards | Lag period (yr) in Gibb et al. (2020) matched in lifetable
Lag period (y) in Gibb et al. (2020) | Lifetime unit risk (95%UB) without ADAFs [per μg Cr(VI)/m^3^] | Lifetime unit risk (95%UB) with ADAFs [per μg Cr(VI)/m^3^]
0 | 1.16 × 10^−2^ | 2.00 × 10^−2^
5 | 1.11 × 10^−2^ | 1.82 × 10^−2^
10 | 1.05 × 10^−2^ | 1.64 × 10^−2^
15 | 9.82 × 10^−3^ | 1.47 × 10^−2^

#### 4.4.5.3 Uncertainty in the Outcome Metric

Lung cancer mortality was ascertained from death certificates according to specific codes from the International Classification of Diseases—eighth edition, and this coding system and those of previous editions have been stable over time. Uncertainty is considered to be very low for lung cancer mortality.

#### 4.4.5.4 Uncertainty Due to Length of Follow-up

There is little potential uncertainty regarding the length of follow-up for cancer mortality. The hire dates among this cohort ranged from August 1, 1950, to December 31, 1974 (the mean date of hire was mid-1957) (Gibb et al., 2000b). Follow-up continued until the date of death, age 96 years, or December 31, 2011, whichever occurred first. Therefore, the range of follow-up was from 37 to 61 years, with a mean of more than 38 years.

#### 4.4.5.5 Uncertainty in Model Form

For lung cancer mortality, the Cox proportional hazards model is a well-established method for epidemiological analyses that is commonly used in cohort studies because this type of survival analysis takes into account differences in follow-up time among the cohort and is approximately linear at low exposures. This model form allows for the evaluation and control of important potential confounding factors such as age and smoking, and for the modeling of exposure as a continuous variable. There is little uncertainty in the choice of model form. Additionally, the R&L model is an alternative approach to the Poisson model and results from this modeling yielded similar results which further reduces the uncertainty in the choice of model form.

#### 4.4.5.6 Uncertainty in Control of Potential Confounding in Modeling Lung Cancer Mortality

It is well known that smoking is a strong independent risk factor for lung cancer. Additionally, tobacco smoke contains chromium (Fresquez et al., 2013), and therefore smokers are expected to be exposed to higher levels of total chromium than nonsmokers. Company medical records provided smoking status at the beginning of employment for 91% of the cohort (Yes/No/Unknown); 74% smoked cigarettes, 16% did not smoke, and smoking status was unknown for 9% (Gibb et al., 2000b). No information on pack-years of smoking or how smoking status may have changed over time was available. As an important potential confounder of the lung cancer mortality analysis, smoking was controlled for in the analyses of lung cancer mortality associated with exposure Cr(VI) (Gibb et al., 2000b; 2015; 2020). Each of the Cox proportional hazards analyses showed that smoking at the beginning of employment was a strong predictor of lung cancer risk. While additional information on the cumulative exposure to smoking may have been helpful to control for smoking more completely, it is clear that as measured, smoking was a strong independent predictor of lung cancer risks and was independent of cumulative Cr(VI) exposure as it was measured at the beginning of employment. There remains some uncertainty as to any potential residual confounding that might be attributed to lack of smoking data on 9% of the cohort and the lack of information on any changes in smoking over time. However, the Baltimore cohort had much better data on smoking compared with the Painesville cohort, and thus the selection of the Baltimore cohort minimizes the potential for confounding by smoking among the available cohorts.

#### 4.4.5.7 Uncertainty Due to Potential Effect Modification

Among the 217 deaths from lung cancer in workers, only four were among nonsmokers (Gibb et al., 2015), and the investigators were unable to evaluate any potential statistical interaction between smoking and Cr(VI) exposure. However, a recent pooled case-control European studies analysis of data (Behrens et al., 2023) from SYNERGY (a large epidemiological cohort exposed to Cr(VI) and four other carcinogens (Peters et al., 2016)) included detailed data on smoking. This analysis controlled for smoking in pack-years and found exposure-response associations with chromium for “never,” “former,” and “current” smokers. Chromium exposure was found to increase lung cancer risks even among never smokers (Behrens et al., 2023). This finding supports the assumption that effects of Cr(VI) exposures occur independently of the effects of smoking.

It is also theoretically possible that the risk of lung cancer mortality estimated in this current assessment is a reflection of a positive synergy between smoking and Cr(VI), and that the adverse effect of Cr(VI) among nonsmokers has been overestimated. However, this possibility cannot be assessed and remains an uncertainty. The unit risk of the lung cancer risk herein would be health protective for any population that had a lower prevalence of smoking than that of the Baltimore cohort.

#### 4.4.5.8 Uncertainty in Low Dose Extrapolation

A common source of uncertainty in quantitative cancer risk assessments generally derives from extrapolating from high doses in animals to low doses in humans. Compared with assessments based on animal data, the uncertainty from low-dose extrapolation in this assessment, which uses occupational epidemiology data, is considered to be low because the POD was well within the range of observed exposure data. The POD for lung cancer was based on 1% extra risk and yielded an LEC_01_ of 0.899 μg Cr(VI)/m^3^ from the Cox analysis and 0.951 μg Cr(VI)/m^3^ from the R&L analysis. Table 2 of Gibb et al. (2015) shows that the median cumulative exposure to CrO_3_ was 0.01 mg CrO_3_/m^3^-years and the 25%-tile of CrO_3_ was 0.001 mg CrO_3_/m^3^-years, and the minimum was zero. Converting to μg Cr(VI)/m^3^, the median was 52 μg Cr(VI)/m^3^ and the 25%-tile was 5.2 μg Cr(VI)/m^3^. Here the PODs appear to be between the minimum and the 25%-tile and thus not outside the range of observed exposures. Thus, there is little uncertainty in extrapolation of the risk function below the POD associated with a 1% BMR.

#### 4.4.5.9 Uncertainty in Extrapolation of Findings in Adults to Children

The analysis of lung cancer mortality using the Cox proportional hazards model assumed that the effect was independent of age, while the analysis using the R&L approach allowed for effects to be different by age group—although this analysis did not provide any estimates of what the age effect was beyond showing that the relatively younger cohort members appeared to be at higher risk of lung cancer mortality than the older cohort members. Given that both of these analyses yielded approximately the same estimate of the IUR, it appears that while there may be an age-related effect of Cr(VI) exposure on the risk of lung cancer, two different analyses that treated age differently yielded essentially the same unit risk when the life-table analysis assumed that the effect was independent of age.

However, Cr(VI) was found to cause cancer by a mutagenic mode of action, and chemical-specific data are not available to address early-life exposure. According to EPA’s Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b), ADAF are applied for children and risks were based on application of age-dependent risk modifiers of an “adult-only” unit risks such that effect were independent of age among people aged 16 years and older. There is some uncertainty that these default ADAF would be health-protective of children although this uncertainty is considered to be low.

### 4.4.6 Previous IRIS Assessment: Inhalation Unit Risk

The previous IRIS assessment for Cr(VI) was posted to the IRIS database in 1998 (U.S. EPA, 1998c). EPA’s 1998 IRIS assessment classified Cr(VI) as “Group A―known human carcinogen by the inhalation route of exposure” under the 1986 guidelines (U.S. EPA, 1986b). This was based on evidence of a causal relationship between inhalation of Cr(VI) and increased incidence of lung cancer in humans in occupational settings. An inhalation unit risk (IUR) for Cr(VI) of 1.2 × 10^−2^ per μg/m^3^ was calculated based on increased incidence of lung cancer in chromate workers from the Painesville, OH cohort (Mancuso, 1975, 1997). Because (Mancuso, 1975, 1997) only provided total chromium data and contained fewer employee records for smoking status, there was higher uncertainty in the 1998 IUR. The lack of Cr(VI) data would have led to an underestimation of risk (because the true Cr(VI) exposure rates were lower relative to total chromium exposure rates), while the lack of smoking data would have led to an overestimation of risk (due to the high prevalence of smoking during this time period).

64 The NTP (2008) 2-year study did not obtain clinical chemistry data in mice or female rats, whereas the 90-day NTP (2007) study contained data for both male and female F344 rats and mice. While chronic data are still preferred, subchronic data were evaluated to assess differences between sexes.

65 Note: the lowest dose (in mg/kg-d Cr(VI) was the same in males and females for the subchronic study. When taking into consideration differences in body weight in the pharmacokinetic model, the daily absorbed dose in males was slightly higher than females (see Appendix C.1.5).

66 While chronic data are preferred for dose-response, only chronic male data were available for this endpoint. Subchronic data from both the 90-day study and 2-year study were modeled to evaluate possible difference between sexes.

67 Some statistical models (Gamma, Dichotomous Hill, Weibull, and LogLogistic) were run with constrained slope or power parameters (≥1) (U.S. EPA, 2012b). As noted in Benchmark Dose Software (BMDS) version 3.2 user guide (U.S. EPA, 2020a), some models with unrestricted coefficients can give complicated shapes, in particular high-degree polynomial models (which produce unrealistic ‘wavy’ results with negative response rates). While Bayesian model averaging is an available feature of BMDS 3.2, only frequentist models were run in this assessment.

68 After accounting for interspecies differences in Cr(VI) reduction, an additional step is needed to account for interspecies differences in tissue concentrations or internal exposure per unit tissue surface area. For the small intestine, an internal dose to the small intestine may be derived by scaling the un-reduced daily Cr(VI) intake rate by intestinal tissue volume (defined as pyloric flux, mg/L-d, by Thompson et al. (2014)). Because organ volumes vary between species by allometric relationships, using the pyloric flux internal dose metric produces similar results as BW^3/4^ scaling of the un-reduced Cr(VI) dose.

69 For female rats, the first nonzero dose had a very high response relative to other dose levels (click here (https://hawcprd.epa.gov/ani/endpoint/100002393/) to see dose-response data). For male rats, the goodness-of-fit p-values were less than 0.1 for all statistical models (even when removing the highest dose, which had a low response relative to other exposure levels). Click here (https://hawcprd.epa.gov/ani/endpoint/100002386/) to see dose-response data for male rats.

70 Data were not amenable to BMD modeling. No change from control was observed at the first nonzero dose.

71 Maternal dam weight is highly correlated to offspring body weight. Because maternal body weight in this study was also decreased, maternal dose is examined here instead of the averaged F0 male and female dose.

72 It was unclear whether standard errors reported for dose groups are based on variation among litters or among pups across litters, and individual-level data are not available.

73 When no biological information is readily available that allows for determining a minimally biological significant response, the BMD Technical Guidance (U.S. EPA, 2012b) recommends a BMR based on one standard deviation (SD).

74 This is in accordance with Recommended Use of Body Weight3/4 as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c).

75 This study was determined to meet PECO criteria in the current assessment; however, the overall confidence was rated uninformative (https://hawc.epa.gov/rob/study/282192/) due to insufficient reporting of the outcomes, survival, and sample sizes of evaluated animals. Normally in situations concerning poor reporting, authors may be contacted for clarifications that may result in upgraded confidence ratings, but this was not possible due to the age of the publication.

76 A large literature database exists presenting qualitative evidence for an association between inhalation Cr(VI) exposure and nasal effects (see ATSDR (2012)). These qualitative studies, which presumably would have varying confidence ratings, were not evaluated in this assessment. Study confidence ratings for the quantitative data in this assessment do not impact EPA’s determination that nasal effects are well established hazards of inhalation Cr(VI) exposure.

77 The cited reports were published by the National Institute for Occupational Safety and Health (NIOSH). Author names listed in these citations are the NIOSH investigators.

78 NIOSH (2020) refers to NIOSH method 7600, published by the National Institute for Occupational Safety and Health (NIOSH), last updated in October 2015 (Issue 3, editors: KE Ashley and PF O’Connor). Cohen et al. (1974) cites the methods developed by Abell and Carlberg that informed NIOSH method 7600 (formerly P&CAM 169). The main features of the 1974 method are consistent with NIOSH 7600. These features are (1) collection of the sample by use of a canister with a PVC filter with pore sizes of 5 μm; (2) extraction of chromate (CrO_4_^2-^) from the filter and derivatization by treatment with a diphenylcarbazide solution resulting in CrO_4_^2-^ diphenylcarbazide; and (3) detection of CrO_4_^2-^diphenylcarbazide by absorption spectrometry at a wavelength of 540 nm.

79 Of the 24 test articles associated with site-specific neoplasia that produced positive, clear or some evidence of carcinogenicity in the oral cavity (NTP, 2020), only one (1,2,3-trichloropropane) induced tumors of the oral cavity in mice. All other test articles induced tumors in the oral cavity of male or female rats. With the exception of Cr(VI), three chemicals were found to induce both oral and small intestine tumors (2,2-bis(Bromomethyl)-1,3-propanediol, C.I. Direct blue 15, C.I. Acid red 114), although they only induced these effects in rats. In general, tumors of the small intestine are rarer in rats (compared with mice), and tumors of the oral cavity are rarer in mice (compared with rats) (see Appendix D.2).

80 Additional characteristics of the probability distributions can be found in Appendix C.1.5 and Appendix D.6.2. According to U.S. EPA Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a): “Slope factors generally represent an upper bound on the average risk in a population or the risk for a randomly selected individual but not the risk for a highly susceptible individual or group. Some individuals face a higher risk and some face a lower risk.” As a result, mean PBPK results are presented in the quantitative cancer assessment.

81 According to raw supplemental data from Kirman et al. (2012), “U” indicates that the result was ≤ the method detection limit (MDL) or client requested reporting limit (CRRL), and the result was reported as the MDL or CRRL (value/square root [2]). “B” indicates that the result, detected by the instrument, was > the MDL but ≤ the method reporting limit (MRL), and that the result was considered an estimate.

82 The beta coefficient describing the function of exposure-response relationship between exposure to Cr(VI) in air, on a continuous scale, and the risk of lung cancer.

83 Here the cumulative exposure is unlagged and untransformed.

84 Conversion of mass of CrO_3_ to mass of Cr(VI) is based on the contribution of the molecular weight (MW) of Cr to MW of CrO_3_. Since the MW of Cr is 51.996 g/mol and the MW of CrO_3_ is 99.99 g/mol, the conversion factor is 51.996/99.99 = 0.52. Units are further converted to μg/m^3^ from mg/m^3^ by multiplying by 1,000 μg/mg.

85 In this Cox proportional hazards regression, the time scale used was age and this controls for age in the model.

86 http://wonder.cdc.gov/ucd-icd10.html.

87 Beta Version. SAS 30NOV18, provided by Randall Smith, National Institute for Occupational Safety & Health.