# 2 LITERATURE SEARCH AND STUDY EVALUATION RESULTS

## 2.1 LITERATURE SEARCH AND SCREENING RESULTS

Literature searches for studies relevant to the assessment of Cr(VI) have been conducted on a yearly basis since 2013, with the most recent update current through August 2022.

The results of the screening process outlined in Section 4.3 of the protocol (see Appendix A) have been posted on the project page for this assessment in the HERO database (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2233), and studies have been “tagged” with appropriate category descriptors (e.g., “included,” “potentially relevant supplemental material,” “excluded”). Results have also been annotated and reported in a literature flow diagram (see Figure 2-1). Note that because studies reporting multiple types of evidence may have more than one tag, the sum of all tags in a category may be greater than the number of individual studies in that category.

Of the 17,927 unique records undergoing title and abstract screening, 14,319 were excluded because they either did not meet PECO criteria outlined in protocol Section 3.3 (see Appendix A) or were not determined to be potentially relevant supplemental material according to the criteria outlined in protocol Section 4.3 (see Appendix A). Using the sorting criteria outlined in protocol Section 4.4 (see Appendix A) for studies not meeting PECO criteria but still having information relevant to the specific aims of the assessment (i.e., “potentially relevant supplemental material”), 3,958 records were identified. Of these, studies were tagged “mechanistic” if there was any indication that they might be useful for mechanistic understanding or might report mechanistically relevant information regarding a health effect not reported in human or animal studies. A total of 142 studies were considered to meet PECO criteria and were eligible for study evaluation (61 human health effects studies and 83 animal health effects studies).

It should be emphasized that the Cr(VI) literature base is vast, and that while all studies meeting PECO criteria are cited in this assessment, not all studies contained in the Cr(VI) HERO database project page are cited.

Figure 2-1 Literature search flow diagram for Cr(VI).

Figure 2-1. Literature search flow diagram for Cr(VI).

## 2.2 STUDY EVALUATION RESULTS

Human and animal studies have evaluated potential respiratory, gastrointestinal (GI) tract, hepatic, hematological, immunological, reproductive, and developmental effects following exposure to Cr(VI). The evidence informing these potential health effects is presented and assessed in Section 3.2. Detailed rationales for each domain and overall confidence rating are available in Health Assessment Workspace Collaborative (HAWC (https://hawc.epa.gov/assessment/499/)).

Overall confidence classifications are presented by effect in Section 3.2. Over 170 studies met PECO criteria (with about an even number of human and animal studies). Many human and animal studies contained information on multiple endpoints. With the exception of male reproductive effects (which had some medium confidence human studies), all human studies meeting PECO criteria that were included in the hazard identification analysis were rated low confidence for all hazard domains. Hazard domains having strong animal databases (containing medium and high confidence studies) were GI, hepatic, hematological, immune, and male and female reproductive. Most animal respiratory studies were medium confidence, and most of the animal developmental studies were rated low confidence.

Two outcomes, nasal lesions, and lung cancer were considered to be well characterized hazards. Therefore, the review of the evidence for nasal effects and lung cancer focused on identifying studies that might improve the quantitative dose-response analysis for this outcome. For human health studies evaluated for dose-response data of nasal effects, three were considered medium (Lindberg and Hedenstierna, 1983; Gibb et al., 2000a; Cohen et al., 1974), and one was considered low confidence (Hanslian et al., 1967). For human health studies evaluated for dose-response data of lung cancer, one was considered high confidence (Gibb et al., 2020), one was considered medium confidence (Proctor et al., 2016), and two were considered low confidence (Gerin et al., 1993; Birk et al., 2006). No quantitative dose-response data for respiratory tract tumors outside of the lung were suitable for IUR derivation. For example, all identified studies of tumors of the nasal cavity were classified as either case reports or review articles without suitable dose-response data. Exclusion rationale for individual studies for lung cancer and noncancer effects of the nasal cavity are provided in Appendix D.4.

Graphical representations focusing on outcome specific ratings are presented in the organ/system-specific integration sections (Hazard Identification, Section 3.2).