# 1 INTRODUCTION

## 1.1 OVERVIEW

This Toxicological Review critically evaluates the publicly available studies on Cr(VI) in order to identify its adverse human health effects and to characterize exposure-response relationships. This assessment was prepared under the auspices of the U.S. Environmental Protection Agency’s (EPA’s) Integrated Risk Information System (IRIS) Program. IRIS assessments are not regulations but provide critical scientific support for human health risk assessments and resulting decisions made by EPA, state and local health agencies, other federal agencies, and international health organizations to protect human health.

This assessment updates a previous IRIS assessment of Cr(VI) (posted in 1998) that included an oral reference dose (RfD) and inhalation reference concentration (RfC) for effects other than cancer, a determination of carcinogenic potential, and inhalation unit risk (IUR) for carcinogenic effects.

As part of the initial steps in assessment development, the IRIS Program undertook scoping and initial problem formulation activities. During scoping activities, the IRIS Program consulted with EPA program and regional offices to identify the nature of the hazard characterization needed, the most important exposure pathways, and the level of detail required to inform Agency decisions. A broad, preliminary literature survey was conducted to assist in identifying the extent of the evidence and health effects that have been studied for Cr(VI). The IRIS Program also undertook problem formulation activities to frame the scientific questions that are a focus of this assessment. A summary of the IRIS Program’s scoping and problem formulation conclusions are contained in the 2014 preliminary packages (U.S. EPA, 2014b, c). The preliminary packages were followed by development of a Systematic Review Protocol (see Appendix A), which presents detailed methods for conducting the full systematic review and dose-response analysis. As discussed in the preliminary materials and protocol, the IRIS assessment includes evaluations of the evidence relevant to all cancer outcomes and noncancer effects for the following potential target systems: respiratory, gastrointestinal (GI) tract, hepatic, hematological, immunological, reproductive, and developmental. For cancer and nasal irritation via the inhalation route, the systematic review focuses on data that may improve the quantitative dose-response analysis, conducted in EPA’s 1998 IRIS assessment.

Appendices for additional systematic review methods and results, pharmacokinetics, dose-response modeling, and public comments are provided as Supplemental Information to this assessment (see Appendices A to G).

### 1.1.1 Background

Elemental chromium is a Group 6 transition metal (atomic number 24 and atomic weight 52) on the periodic table, existing in nature in the form of various oxide minerals (Anger et al., 2005). It is present in the Earth’s crust and has oxidation states ranging from −2 to +6, with the +3 (trivalent) and +6 (hexavalent) states being the most common (Losi et al., 1994). Chromium in the environment can originate from both natural and anthropogenic sources (discussed in detail in Section 1.1.3) (USGS, 1995; Pacyna and Nriagu, 1988; Johnson et al., 2006; Calder, 1988). Cr(VI) compounds are used for corrosion inhibition, pigment manufacturing (including textile dyeing, printing inks, and colored glass and plastic), and metal finishing (chrome plating/electroplating) (NTP, 2011; NIOSH, 2013). Cr(VI) has been used in wood preservatives [as chromated copper arsenate (CCA) in pressure treated wood; (Barnhart, 1997; ATSDR, 2012)]; however, this use began to decline in 2003 due to a voluntary phaseout of all residential uses of CCA pressure treated wood (NTP, 2011; Bedinger, 2015). Other uses for Cr(VI) that have been discontinued in the United States include leather tanning and corrosion inhibition within cooling systems (NTP, 2011; NIOSH, 2013). Cr(VI) is also a byproduct of processes in the iron and steel industries (Shaw Environmental, 2006).

### 1.1.2 Chemical Properties

A summary of the Cr(VI) compounds assessed in the human, animal, and mechanistic studies considered pertinent to this assessment are contained in Table 1-1. This table is not an exhaustive list of all Cr(VI) species that are relevant to human exposure but reflects those with data to inform a human health assessment. Compounds of chromium complexed to other metals that could potentially confound the results (such as lead chromate, barium chromate, zinc chromate, copper dichromate, strontium chromate) were not included. A majority of the Cr(VI) compounds evaluated by the human, animal, and mechanistic studies relevant to this assessment are known to be highly water soluble. Calcium chromate, a form with low water solubility, was used in some animal bioassays and pharmacokinetics studies and was therefore considered. Inhalation pharmacokinetics differ between soluble and insoluble forms of Cr(VI) (OSHA, 2006) (see Section 3.1). This assessment will not make separate determinations of toxicity or carcinogenicity of soluble vs. insoluble Cr(VI) compounds because the aim is to evaluate the toxicity and carcinogenicity of Cr(VI) in all forms. Where applicable, issues related to solubility and particle size that may impact study or data interpretations are discussed during study evaluation, hazard identification, and dose-response.

Cr(VI) can exist as chromate (CrO_4_^2−^), hydrochromate (HCrO_4_^2−^) and dichromate (Cr_2_O_7_^2−^) anions, whose concentrations at equilibrium depend on the metal concentration in the solution and pH (Brito et al., 1997). At physiological conditions (pH 7.4) and micromolar Cr(VI) concentrations, the major form of Cr(VI) is chromate and the minor form is hydrochromate, with the latter becoming a dominant form at pH ≤ 6 (Cieślak-Golonka, 1996). These pH-relationships between Cr(VI) species were incorporated into the gastric reduction model used in this assessment (Schlosser and Sasso, 2014). Because multiple Cr(VI) compounds are discussed in this assessment, all exposure levels were converted to Cr(VI) equivalents (see Protocol Section 8.2, Appendix A).^1^ Even though the physical properties differ between compounds, they are all ionized to Cr(VI) in the body and are considered to exert the same pharmacological and toxicological effects (U.S. EPA, 2008).

Table 1-1 Chemical identity and physicochemical properties of Cr(VI)

Name | Calcium chromate | Sodium chromate | Sodium dichromate | Sodium dichromate, dihydrate | Potassium chromate | Potassium dichromate | Chromium trioxide^b^ | Chromic acid^b,c^
CASRN | 13765-19-0 | 7775-11-3 | 10588-01-9 | 7789-12-0 | 7789-00-6 | 7778-50-9 | 1333-82-0 | 7738-94-5 (H_2_CrO_4_); 13530-68-2 (H_2_Cr_2_O_7_)
Synonyms | Calcium chromate(VI); calcium chrome yellow; calcium monochromate; gelbin; yellow ultramarine; chromic acid, calcium salt | Sodium chromate(VI); chromium disodium oxide; disodium chromate; rachromate; chromic acid, disodium salt; chromate of soda | Sodium dichromate(VI); sodium bichromate; dichromic acid, disodium salt; bichromate of soda | Dichromic acid, disodium salt, dihydrate | Potassium chromate(VI); bipotassium chromate; dipotassium chromate; chromate of potash; tarapacaite; chromic acid, dipotassium salt | Potassium dichromate(VI); bichromate of potash; potassium bichromate; dipotassium bichromate; dipotassium dichromate; dipotassium dichromium heptaoxide; lopezite; dichromic acid dipotassium salt | Chromium(VI) oxide; hexavalent chromium oxide; chromic trioxide; chromic anhydride | Chromic(VI) acid; chromium hydroxide oxide; dichromic acid (H_2_Cr_2_O_7_)
Structure | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Molecular weight | 156.07 | 161.972 | 261.965 | 297.995 | 194.188 | 294.181 | 99.993 | 118.008 (H_2_CrO_4_) 218.001 (H_2_Cr_2_O_7_)
Molecular formula | CaCrO_4_ | Na_2_CrO_4_ | Na_2_Cr_2_O_7_ | Na_2_Cr_2_O_7_•2H_2_O | K_2_CrO_4_ | K_2_Cr_2_O_7_ | CrO_3_ | H_2_CrO_4_; H_2_Cr_2_O_7_
Conversion factor ^a^ | 0.333 | 0.321 | 0.397 | 0.349 | 0.268 | 0.353 | 0.520 | 0.441 (H_2_CrO_4_) 0.477 (H_2_Cr_2_O_7_)
Melting point | 1020°C Anger et al. (2005); decomposition | 794°C Lide (2008) | 357°C Lide (2008) | 85°C Lide (2008); decomposition | 974°C Lide (2008) | 398°C Lide (2008) | 197°C Lide (2008) | Not applicable
Density | 3.12 g/cm^3^ Anger et al. (2005) | 2.72 g/cm^3^ Lide (2008) | 2.52 g/cm^3^ Anger et al. (2005) | 2.35 g/cm^3^ Lide (2008) | 2.73 g/cm^3^ Lide (2008) | 2.68 g/cm^3^ Lide (2008) | 2.7 g/cm^3^ Lide (2008) | Not applicable
Water solubility | 4.5 g/100 g H_2_O (4.3 wt%) at 0°C Anger et al. (2005) | 87.6 g/100 g H_2_O at 25°C Lide (2008) | 187 g/100 g H_2_O at 25°C Lide (2008) | 272.9 g/100 g H_2_O (73.18 wt%) at 20°C Anger et al. (2005) | 65.0 g/100 g H_2_O at 25°C Lide (2008) | 15.1 g/100 g H_2_O at 25°C (Lide, 2008) | 169 g/100 g H_2_O at 25°C Lide (2008) | Not applicable
Stability/reactivity | Decomposes at 1,000°C Lide (2008); oxidizing agent Lewis and Hawley (2007) | Hygroscopic Anger et al. (2005) | Strongly hygroscopic; decomposes above 400°C Lide (2008); strong oxidizing agent Anger et al. (2005) | Very hygroscopic, deliquesces in air; strong oxidizing agent in acid solution Lide (2008); Anger et al. (2005) | Nonhygroscopic (Anger et al., 2005). Strong oxidizing agent, may explode in contact with organic materials Lewis and Hawley (2007) | Nonhygroscopic; decomposes at 500°C Lide (2008); Anger et al. (2005) | Deliquescent; decomposition begins above 198°C Anger et al. (2005); strong oxidizing agent O’Neil et al. (2006) | Strong oxidizing agent Anger et al. (2005)

Synonyms, structures, and molecular formulas and weights were obtained from ChemID Plus (https://chem.nlm.nih.gov/chemidplus), unless otherwise noted.

a Mass conversion factor from parent compound to Cr(VI) units.

b Chromic acid is formed in aqueous solution when chromium(VI) oxide is dissolved in water; it cannot be isolated as a pure compound out of solution (Page and Loar, 2004; Anger et al., 2005). The term chromic acid is sometimes used to reference chromium(VI) oxide; however, it should be noted that there is a structural difference between the anhydrous substance chromium(VI) oxide and the aqueous chromic acid that forms when the oxide is dissolved in water.

c Chromic acid exists in solution as both H_2_CrO_4_ and H_2_Cr_2_O_7_ (Page and Loar, 2004; Cotton et al., 1999; Anger et al., 2005). H_2_CrO_4_ is the main species in basic solutions (pH > 6) while H_2_Cr_2_O_7_ is the main species in strongly acidic solutions (pH < 1) (Page and Loar, 2004; Cotton et al., 1999; Anger et al., 2005). Both species are present in equilibrium in solutions that have a pH value between 2 and 6 (Page and Loar, 2004; Cotton et al., 1999; Anger et al., 2005).

### 1.1.3 Sources, Production, and Use

#### 1.1.3.1 Soil

The EPA Toxics Release Inventory (TRI) estimates approximately 53 million pounds of chromium and chromium compounds were released to the environment via land releases (such as landfills, land treatment, and surface impoundments, excluding underground injections) (U.S. EPA, 2018). Sources of chromium releases into soil include the disposal of commercial products that contain chromium, coal fly ash and bottom fly ash from electric utilities and other industries, solid wastes from metal manufacturing and chrome-plating facilities, chromate production waste, agricultural and food wastes, leather tannery waste, and cooling tower water containing rust inhibitors (U.S. EPA, 2011b; Pellerin and Booker, 2000; Oregon DEQ, 2014; Nriagu and Pacyna, 1988; Burke et al., 1991; ATSDR, 2012). Air deposition to soil from combustion processes also occurs.

Cr(III) in soil may be present predominantly as chromium hydroxide (Cr(OH)_3_) or chromium oxide (Cr_2_O_3_) (Kim and Dixon, 2002; Apte et al., 2006). These Cr(III) forms have low solubility and reactivity. Cr(VI) may exist in soil as chromate (CrO_4_^–2^), chromic acid (HCrO_4_^–^), dichromate (Cr_2_O_7_^–2^), and chromate salts (BaCrO_4_, CaCrO_4_, PbCrO_4_, ZnCrO_4_) (Kim and Dixon, 2002; ATSDR, 2012; Apte et al., 2006). Conversion of Cr(VI) to Cr(III) may occur in the environment under reducing conditions (by ferrous iron, sulfides, and organic matter), while conversion of Cr(III) to Cr(VI) may occur under oxidizing conditions (by manganese oxide minerals) (Oze et al., 2004; Oze et al., 2007; McClain et al., 2017; Kim and Dixon, 2002; Jardine et al., 2011; Hausladen and Fendorf, 2017; Hausladen et al., 2018; Fendorf, 1995; Fendorf et al., 2000; Cummings et al., 2007). Fire-induced oxidation of Cr(III)-substituted iron oxides in soils may also occur during wildfires (Burton et al., 2019).

Most Cr(III) compounds are insoluble in water and immobile in soils (which helps inhibit oxidation), while most Cr(VI) compounds are readily soluble in water and highly mobile and bioavailable (Fendorf, 1995; Fendorf et al., 2000). In addition to being stabilized by low solubility and mobility, Cr(III) compounds are more thermodynamically stable than Cr(VI) compounds under most pH values encountered in the environment (Fendorf, 1995). Therefore, the predominant direction of chromium transformation in the environment is Cr(VI) →Cr(III). In addition, Cr(VI) absorbed by plants is reduced to Cr(III) in the roots and distributed in plant tissue as Cr(III) (Zayed et al., 1998; Lytle et al., 1998; Hamilton et al., 2018). See Figure 1-1.

Figure 1-1 Sources of Cr(VI) in soil and groundwater.

Adapted from Hausladen et al. (2018).

#### 1.1.3.2 Water

The EPA Toxics Release Inventory (TRI) estimates approximately 66,000 pounds of chromium and chromium compounds were released to the environment via surface water discharges, and 315,000 pounds were discharged for wastewater treatment in 2019 (U.S. EPA, 2018). Data from USEPA’s Discharge Monitoring Report (DMR) estimates that approximately 90,000 pounds of Cr(VI) was discharged in 2020 (U.S. EPA, 2014a). Most chromium released into water from anthropogenic sources is ultimately deposited in sediment. Chromium in the aqueous phase is mostly present as soluble Cr(VI) or as soluble Cr(III) complexes. Reduction of Cr(VI) to Cr(III) can occur in the presence of reducing agents (e.g., organic matter, hydrogen sulfide, sulfur, iron sulfide, ammonium, nitrate). The reduction half-life of Cr(VI) in water can be rapid (ranging from instantaneously to a few days) when reducing agents are present under anaerobic conditions but can extend from 4–140 days in water with soil and organic sediment (Saleh et al., 1989). Oxidation of Cr(III) to Cr(VI) can also occur within aquifers and water treatment systems (U.S. EPA, 1986a; Chebeir and Liu, 2016). The ratio of Cr(VI) to Cr(III) has been measured to be higher in groundwater than in surface water (Frey et al., 2004). Oxidizing conditions within soil, as well as the natural Cr(VI) content of soil and rocks, also affect Cr(VI) content of water (Vengosh et al., 2016). Above-average groundwater levels of Cr(VI) have been reported in several areas in the Western US (U.S. EPA, 2014d).

#### 1.1.3.3 Air

Approximately 222,840 pounds of chromium and chromium compounds were released from fugitive and point sources into air from reporting facilities in 2020 (U.S. EPA, 2021c). According to data from the 2017 EPA National Emissions Inventory (NEI), approximately 64,208 pounds of Cr(VI), 1,392 pounds of chromic (VI) acid, 86 pounds of Chromium (VI) Trioxide, and 373,891 pounds of chromium (III) were released into the air nationwide (U.S. EPA, 2021b). The NEI includes additional emissions sources not reported under TRI (i.e., mobile sources). Atmospheric chromium particles resulting from industrial emissions have been reported to have a mass mean aerodynamic diameter (MMAD) of less than 10 μm, were found to remain airborne for 7–10 days, and were subject to long-range transport (Kimbrough et al., 1999). Atmospheric particulate matter is deposited on land and water via wet and dry deposition, and metals may deposit at a higher rate in urban areas relative to rural and remote locations (Schroeder et al., 1987). Transport of chromium from water to the atmosphere is possible via transport in windblown sea salt sprays (Nriagu, 1989). Major atmospheric chromium emissions from anthropogenic sources in the United States are outlined in Table 1-2.

Table 1-2 Major anthropogenic sources of atmospheric chromium in the United States [adapted from ATSDR (2012)]

Industrial processes and production | Cooling towers
Combustion of coal and oil | Utility industry cooling towers
Ferrochromium production | Chemical manufacturing cooling towers
Chromium chemical manufacturing | Petroleum refining cooling towers
Chrome plating | Glass manufacturing cooling towers
Chrome ore refining | Primary metal cooling towers
Refractory production | Comfort cooling towers
Cement production | Textile manufacturing cooling towers
Specialty/steel production | Tobacco cooling towers
Sewage sludge incineration | Tire and rubber cooling towers
Municipal refuse incineration

Data of annual Cr(VI) emissions in the US can be obtained from the EPA National Emissions Inventory (U.S. EPA, 2016a).

Depending on the emission source, different forms of Cr(VI) may be emitted (i.e., Cr(VI) acid mists/dissolved aerosols, and Cr(VI) dusts). While information is limited regarding non-occupational inhalation exposures to chromic acid mists for the general U.S. population, residents of fence-line communities may be exposed to multiple forms of Cr(VI) (OAQPS, 2012). Chrome-plating facilities and private residencies may exist in close proximity in mixed land use communities (CARB, 2004; CalEPA, 2003). Chromium trioxide (CrO_3_) is the acidic anhydride of chromic acid (H_2_CrO_4_). Chromic acid in mists or vapors dehydrates to CrO_3_ upon evaporation, and some CrO_3_ may convert to H_2_CrO_4_ in moist environments (including the respiratory tract).

### 1.1.4 Environmental Occurrence

The mean soil concentration of total chromium in the United States is approximately 36 mg/kg (Smith et al., 2013), and the ratio of Cr(VI) to Cr(III) depends on several factors (such as soil pH). Nationwide data for speciated chromium are unavailable, although some site-specific soil concentrations of Cr(VI) have been reported. For example, soil Cr(VI) concentrations in Montana were mostly below the limit of detection of 0.29 mg/kg (Hydrometrics, 2013). Cr(VI) concentrations near industrial facilities in Portland, Oregon were typically below 1 mg/kg but were measured as high as 3 mg/kg (Oregon DEQ, 2016a, c). Bioaccumulation of Cr(VI) or Cr(III) from soil to above ground plants, or biomagnification of chromium in terrestrial or aquatic food chains, is not expected to occur (ATSDR, 2012).

Public water system data from EPA’s Third Unregulated Contaminant Monitoring Rule (UCMR3),^2^ includes both groundwater and surface water sources (U.S. EPA, 2014d). Mean Cr(VI) concentrations in public water systems averaged approximately 0.48 μg/L for large systems (U.S. EPA, 2014d). There was wide variability by region (see Figure 1-2), and a maximum concentration of 97.4 μg/L.

Ambient air concentrations of Cr(VI) in the United States typically range from 0.01 to 0.05 ng/m^3^ (U.S. EPA, 2016c),^3^ but have been measured at values above 1 ng/m^3^ for urban and industrial areas (Oregon DEQ, 2016b; Huang et al., 2014). Historically, Cr(VI) concentrations measured in ambient air downwind of industrial facilities emitting Cr(VI) (such as chrome platers) have been found to be highly correlated with concentrations measured at the facilities (SCAQMD, 2016). Between May 2001–May 2002, residential air near chrome-plating facilities in San Diego, CA were measured up to 22.0 ng/m^3^ Cr(VI) (CalEPA, 2003, 2004).

Figure 1-2 Drinking water chromium (VI) concentrations in the United States by EPA region.^4^

Boxplots are based on the average values of samples of large public water systems within the region, from EPA's Third Unregulated Contaminant Monitoring Rule (UCMR3) (U.S. EPA. 2014d). Boxes represent interquartile ranges. Whiskers are 1.5× the interquartile range away from the 25th/75th percentiles.

### 1.1.5 Potential for Human Exposure

#### 1.1.5.1 General Population

General population exposures to Cr(VI) occur via inhalation of ambient air, ingestion of water or food, and non-dietary ingestion of soil or dust. Most human exposure to total chromium (sum of Cr(VI) and Cr(III)) is from dietary intake of Cr(III) that is naturally present in foods (Wisconsin DHS, 2010). Cr(III) is generally understood to be essential to normal glucose, protein, and fat metabolism and is thus an element with an Adequate Intake (AI)^5^ values (IOM, 2011), although no Recommended Daily Allowance (RDA) has been established due to insufficient evidence to establish a level of Cr(III) that is necessary for human health (Vincent, 2013; Vincent, 2017; Stearns, 2000; NIH, 2017). Dermal exposure may also occur during the use of consumer products that contain chromium, such as some metals or leather treated with chromium-containing compounds (NTP, 2011; ATSDR, 2012).

Quantifying the non-dietary exposure to Cr(VI) via soil ingestion (hand-to-mouth contact and pica behavior in children) is uncertain due to limited data on chromium speciation in soil. As noted earlier, the Cr(VI)/Cr(III) concentration ratio in soil can vary due to factors such as soil pH and mineral content, and no nationwide data on soil Cr(VI) currently exist. EPA’s Office of Pesticide Programs (OPP), in its reregistration eligibility decision (RED) for chromated copper arsenate (CCA) pesticides (U.S. EPA, 2008), determined that dietary, residential, or other non-occupational exposures to Cr(VI) was not expected to occur from wood preservative uses of chromated arsenicals.

Dietary exposure to Cr(VI) via food ingestion is uncertain due to limited data on speciation in food. Typical total chromium (sum of Cr(VI) and Cr(III)) levels in most foods have been reported to range from <10 to 1,300 μg/kg, with the highest concentrations being found in meat, fish, fruits, and vegetables (WHO, 2003). Dietary total chromium intake in the general U.S. population has been estimated to range from 0.293–0.867 μg/kg-day (Moschandreas et al., 2002; ATSDR, 2012). It is possible that a fraction of this intake is in the form of Cr(VI) (Hamilton et al., 2018). Mathebula et al. (2017) found that 33%–73% of total chromium in bread may exist as Cr(VI) (at concentrations between 19–64 μg/kg), and that oxidation of Cr(III) to Cr(VI) can occur from toasting. That study also detected Cr(VI) in breakfast cereals at concentrations between 41–470 μg/kg. Soares et al. (2010) estimated that 12% of total chromium in bread was hexavalent. However, nationwide data for Cr(VI) content in food is limited. It is assumed that (total) chromium exposure to infants via breastmilk is low (EFSA CONTAM Panel, 2014); however, no studies investigating levels of speciated Cr(VI) in human milk were identified.

According to data collected between 2013 and 2015 under EPA's Third Unregulated Contaminant Monitoring Rule (UCMR3), Cr(VI) has been reported above the minimum reporting limit (0.03 μg/L) in approximately 90% of public water systems in the United States (U.S. EPA, 2014d). More detailed concentration data for Cr(VI) in large U.S. water systems are provided in Section 1.1.4 (above) and in Appendix C.4. According to this information, drinking water is expected to be a significant source of exposure for the general population.

The general population may be exposed to Cr(VI) in air but will likely receive a lower inhaled dose when compared with the oral ingestion pathway. A 70 kg individual drinking 2L/day water containing 0.5 μg/L Cr(VI) will ingest a dose of 1.4 × 10^−5^ mg/kg-day Cr(VI). A 70 kg individual with a respiratory rate of 20 m^3^/day inhaling air containing 4 × 10^−5^ μg/m^3^ Cr(VI) will inhale Cr(VI) at a body weight-normalized rate of 1.1 × 10^−8^ mg/kg-day. Both air and water concentrations may vary from the approximate mean values by a factor of 100 in extreme cases (see Appendix C.4). Only in extreme cases is it possible for the inhaled dose to be comparable to the ingested dose for people living in an area with low Cr(VI) in water and high Cr(VI) in air.

Inhalation of Cr(VI) in water droplets during showering can also occur. Since Cr(VI) cannot volatilize, and because Cr(VI) compounds are typically water soluble, the metal will exist only in water droplets and aerosols. An analysis of this exposure pathway was performed by California EPA and determined that a 70-kg adult breathing 20 m^3^ of air per day, taking a 10-minute shower would inhale 27 mg of liquid water per shower (3.86 × 10^−7^ L/kg-day) (CalEPA, 2011). Assuming water contains 0.5 μg/L Cr(VI) yields an inhaled dose of 1.9 × 10^−10^ mg/kg-day, which is five orders of magnitude lower than the dose resulting from 2 L/day water ingestion at the same Cr(VI) concentration (1.4 × 10^−5^ mg/kg-day).

Humans may be exposed via inhalation and incidental ingestion of house dust. A study of house dust in areas with no known soil contamination by Cr(VI) in New Jersey measured a mean Cr(VI) surface loading of 10 μg/m^2^ (maximum of 169.3 μg/m^2^), and mean Cr(VI) concentration of 4.6 μg/g (maximum of 56.6 μg/g) (Stern et al., 2010). Nationwide data of Cr(VI) in house dust are unavailable.

#### 1.1.5.2 Occupational Exposure

Occupational exposures to Cr(VI) occur primarily via inhalation or dermal contact (NIOSH, 2013) and typically exceed non-occupational exposures (NTP, 2011). Workers can potentially inhale Cr(VI) during its processing or manufacture and when working with mixtures containing the chemical or chemical precursors. Dermal exposures may potentially result from the splashing or spilling of chromium-containing materials that contact the skin or from contact with construction materials containing Portland cement (due to a Cr(VI) impurity) (NIOSH, 2013). Portal-of-entry sites may be exposed via hand-to-mouth contact and hand-to-nose contact (OSHA, 2006), and the extent of these transfers depends on the industry, exposure matrix, and workplace hygiene practices (Cohen et al., 1974). Industries that may have workers who are in contact with Cr(VI)-containing materials include stainless-steel welding, painting, electroplating, steel mill, iron and steel foundries, wood preserving, and occupations that produce paints, coatings, inks, plastic colorants, chromium catalyst, and other chemicals (such as chromium dioxide and chromium sulfate) (NIOSH, 2013). Other industries with limited potential exposures to Cr(VI) compounds include textile dyeing, glass production, printing, leather tanning, brick production, woodworking, solid waste incineration, oil and gas well drilling, construction and Portland cement production (NTP, 2011; NIOSH, 2013). EPA’s OPP, in its RED for CCA pesticides (U.S. EPA, 2008), determined that inhalation exposure to chromium may occur from these pesticide components in occupational settings. Because exposure to Cr(VI) outside of the workplace is possible via contaminated clothing, OSHA (2006) implemented workplace rules to ensure that clothing contaminated with Cr(VI) is not carried to employees’ cars and homes (which would expose both the workers and other individuals). Table 1-3 provides a list of industries that are potential sources of chromium exposure.

Table 1-3 Industries and occupations that may be sources of chromium exposure

Group 1: Industry sectors where majority of occupational exposures occur to hexavalent chromium | Group 2: Industry sectors with limited potential for occupational exposure to hexavalent chromium
Electroplating | Chromium Dioxide Producers
Welding | Chromium Dye Producers
Painting | Chromium Sulfate Producers
Producers of Chromates and Related | Chemical Distributors
Chemicals from Chromite Ore | Textile Dyeing
Chromate Pigment Production | Producers of Colored Glass
Chromated Copper Arsenate Producers | Printing
Chromium Catalyst Production | Leather Tanning
Paint and Coatings Production | Chromium Catalyst Users
Printing Ink Producers | Producers of Refractory Brick
Plastic Colorant Producers and Users | Woodworking
Plating Mixture Production | Solid Waste Incineration
Wood Preserving | Oil and Gas Well Drilling
Chromium Metal Production | Portland Cement Producers
Steel Mills | Non-Ferrous Superalloy Producers and Uses
Iron and Steel Foundries | Construction
| Producers of Pre-Case Concrete Products

Source: Analysis performed by OSHA (Shaw Environmental, 2006).

## 1.2 SUMMARY OF ASSESSMENT METHODS

The systematic review and dose-response methods used to conduct this assessment are summarized in the remainder of this section. A detailed description of these methods is provided in the preliminary materials released in 2014 (U.S. EPA, 2014b, c) and in the Systematic Review Protocol for Cr(VI), released in 2019 (U.S. EPA, 2019), which has been updated to reflect refinements made to the protocol during the assessment process. A link to the updated protocol can be found in the Supplementary Materials released with this Toxicological Review in Appendix A.

The Cr(VI) protocol (U.S. EPA, 2019) was made public prior to the release of the draft IRIS Handbook (U.S. EPA, 2020b), and therefore reflects methodology (i.e., literature search, screening, study evaluation, evidence synthesis and integration) that was updated in 2022 (U.S. EPA, 2022) to incorporate updates to assessment methodology as recommended in a report by the National Academies of Sciences, Engineering, and Medicine (NASEM) (NASEM, 2021). The assessment team considered the revisions made to the Handbook in response to the NASEM report and concluded that the changes would not fundamentally impact the previously initiated literature search, screening, overall study evaluation ratings, evidence synthesis judgments, or overall evidence integration conclusions.

### 1.2.1 Literature Search and Screening

Literature search strategies were developed using key terms and words related to the PECO criteria and potentially relevant supplemental material. Relevant subject headings and text-words were crafted into a search strategy that was designed to maximize the sensitivity and specificity of the search results. The search strategy was run, and the results were assessed to ensure that all previously identified relevant primary studies were retrieved in the search. Because each database has its own search architecture, the resulting search strategy was tailored to account for the unique search functionality of each database.

The following databases were searched:

- PubMed (https://www.ncbi.nlm.nih.gov/pubmed/) (National Library of Medicine)
- Web of Science (https://apps.webofknowledge.com/) (Thomson Reuters)
- Toxline (https://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?TOXLINE) (National Library of Medicine)^6^

Searches were not restricted by publication date, and no language restrictions were applied. Web of Science results were limited using the research areas filter. All Web of Science research areas identified in the search results were prioritized by a technical advisor as high priority (e.g., toxicology), low priority (e.g., chemistry), and not relevant (e.g., forestry). Literature searches were conducted in bibliographic databases as described in Appendix B and uploaded to EPA’s Health and Environmental Research Online (HERO) database.^7^

Additional relevant literature not found through database searching was sought by:

- Manually searching citations from review articles and studies considered to meet PECO criteria after screening (“included” studies).
- Searches of gray literature, including primary studies that are not indexed in databases of peer-reviewed literature (e.g., technical reports from government agencies or scientific research groups; unpublished laboratory studies conducted by industry; working papers from research groups or committees; and white papers), or other nontypical searches. Gray literature is typically identified by searching the EPA Chemical Dashboard (https://comptox.epa.gov/dashboard) during problem formulation, by engaging with technical experts, and during solicitation of Agency, interagency, and public comment at multiple steps in the IRIS process.
- “Backward” searches (to identify articles cited by included studies, reviews, or prior assessments by other agencies).

The results returned (i.e., the number of “hits” from each electronic database or other literature source), including the results of any literature search updates, are documented in the literature flow diagrams, which also reflect the literature screening decisions (see Section 2.1).

The IRIS Program takes extra steps to ensure identification of pertinent studies by (1) encouraging the scientific community and the public to identify additional studies and ongoing research; (2) searching for publicly available data submitted under the Toxic Substances Control Act and the Federal Insecticide, Fungicide, and Rodenticide Act; and (3) considering late breaking studies that would impact the credibility of the conclusions, even during the review process. Studies identified after peer review begins will only be considered for inclusion if they meet the PECO criteria and may fundamentally alter the assessment’s conclusions.

### 1.2.2 Evaluation of Individual Studies

The detailed approaches used for the evaluation of epidemiologic and animal toxicology studies used in the Cr(VI) assessment are provided in the protocol (see Appendix A). The general approach for evaluating health effect studies meeting PECO criteria is the same for epidemiology and animal toxicology studies although the specifics of applying the approach differ; thus, they are described in detail in protocol Sections 6.2 and 6.3, respectively, in Appendix A.

- The key concerns for the review of epidemiology and animal toxicology studies are potential bias (factors that affect the magnitude or direction of an effect in either direction) and insensitivity (factors that limit the ability of a study to detect a true effect; low sensitivity is a bias toward the null when an effect exists). In terms of the process for evaluating individual studies, two or more reviewers independently arrive at judgments regarding the reliability of the study results (reflected as study confidence determinations; see below) with regard to each outcome or outcome grouping of interest; thus, different judgments are possible for different outcomes within the same study. The results of these reviews are tracked within EPA’s version of the Health Assessment Workplace Collaboration (HAWC (https://hawcprd.epa.gov/assessment/499/)).
- To develop these judgments, each reviewer assigns a category of good, adequate, deficient (or not reported, which generally carries the same functional interpretation as deficient), or critically deficient (listed from best to worst methodological conduct; see Section 6.1 of the protocol in Appendix A for definitions) to each evaluation domain representing the different characteristics of the study methods that were evaluated based on the criteria outlined in HAWC. Reviewers assigning categories to each domain are guided by core and prompting questions as well as additional considerations specific to Cr(VI) or the outcome of interest. Exposure-specific considerations in epidemiology studies are described in Section 6.2. Briefly, air concentration measurements were preferred to biomarker measurements. Studies in which human exposure was quantified by measurements of total chromium in urine, blood, plasma, or erythrocytes were considered for determination of hazard only if conducted in workers with known occupational exposure to Cr(VI).

Once all evaluation domains were evaluated, the identified strengths and limitations are considered as a whole by the reviewers in order to reach a final study confidence classification:

- High confidence: No notable deficiencies or concerns were identified; the potential for bias is unlikely or minimal, and the study used sensitive methodology.
- Medium confidence: Possible deficiencies or concerns were noted, but the limitations are unlikely to be of a notable degree or to have a notable impact on the results.
- Low confidence: Deficiencies or concerns were noted, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Low confidence results were given less weight compared with high or medium confidence results during evidence synthesis and integration (see Section 1.2.4 and 1.2.5).
- Uninformative: Serious flaw(s) were identified that make the study results unusable. Uninformative studies were not considered further, except to highlight possible research gaps.

Using the HAWC platform (and conflict resolution by an additional reviewer, as needed), the reviewers reached a consensus judgment regarding each evaluation domain and overall (confidence) determination. The specific limitations identified during study evaluation were carried forward to help inform the synthesis (see Section 1.2.4) within each body of evidence for a given health effect along with other considerations. Additional details regarding study evaluation are provided in Sections 6.1–6.5 of the protocol (see Appendix A).

### 1.2.3 Data Extraction

The detailed data extraction approach is provided in Section 8 and Appendix B of the protocol (see Appendix A). Animal data extraction and content management were carried out using HAWC, while data extracted from epidemiology studies were summarized in tabular format in the assessment and appendices. Studies evaluated as being uninformative were not considered further and study details are not summarized. In addition, study details and results for outcomes not prioritized during PECO refinement (e.g., kidney and neurological) were not extracted or were only partially extracted (see Appendix A). The same was typically true for low confidence studies where a number of medium and high confidence studies were available, unless the low confidence studies included study designs lacking in the higher confidence studies (e.g., testing lower exposure levels, or susceptible populations or life stages). The level of extraction for specific outcomes within a study may differ (i.e., ranging from a narrative to full extraction of dose-response effect size information). Data extraction was performed by one member of the evaluation team and checked by at least one other member.

For animal data already extracted to evidence tables released in 2014 (U.S. EPA, 2014b), data extraction procedures depended on data type (e.g., dichotomous, continuous, or qualitative). For human data already extracted to evidence tables released in 2014 (U.S. EPA, 2014c), data extraction procedures depended on the study evaluation judgment and the study design. Large-scale epidemiological datasets, which are typically stored in databases and under the custody of scientific researchers or institutions, were not extracted or uploaded into HAWC. A detailed discussion of the methods used for data extraction is provided in Section 8 of the protocol (see Appendix A). Extracted data are available in HAWC (https://hawcprd.epa.gov/assessment/499/endpoints/) and are also summarized in tabular or graphical form in the hazard identification and dose-response sections.

### 1.2.4 Evidence Synthesis and Integration

For the purposes of this assessment, evidence synthesis and integration are considered distinct but related processes (see Protocol Sections 9 and 10, Appendix A for full details). For each assessed health effect, the evidence syntheses provide a summary discussion of each body of evidence considered in the review that directly informs the integration across evidence to draw an overall judgment for each health effect. The available human and animal evidence pertaining to the potential health effects are synthesized separately, with each synthesis providing a summary discussion of the available evidence that addresses considerations regarding causation that are adapted from (Hill, 1965). Mechanistic evidence and other supplemental information are also synthesized to address key science issues and/or to help inform key decisions regarding the human and animal evidence.

The syntheses focus on describing aspects of the evidence that best inform causal interpretations, including the exposure context examined in the sets of available studies. The human and animal health effects evidence syntheses are based primarily on studies of high and medium confidence. Low confidence studies may be used if few or no studies with higher confidence are available to help evaluate consistency, or if the study designs of the low confidence studies address notable uncertainties in the set of high or medium confidence studies on a given health effect. If low confidence studies are used, then a careful examination of risk of bias and sensitivity with potential impacts on the evidence synthesis conclusions is included in the narrative. The synthesis of mechanistic evidence and other supplemental information informs the integration of health effects evidence for both hazard identification (i.e., biological plausibility of the available human or animal evidence; inferences regarding human relevance, or the identification of susceptible populations and life stages across the human and animal evidence) and dose-response evaluation.

For each assessed health effect, following the evidence syntheses, integrated judgments are drawn across all lines of evidence. During evidence integration, a structured and documented process was used, as follows:

- Building from the separate syntheses of the human and animal evidence, the strength of the evidence from the available human and animal health effect studies was summarized in parallel, but separately, using a structured evaluation of an adapted set of considerations first introduced by Bradford Hill (Hill, 1965). These summaries incorporate the relevant mechanistic evidence (or MOA understanding) that informs the biological plausibility and coherence within the available human or animal health effect studies.
- The strength of the animal and human evidence was considered together in light of inferences across evidence streams. Specifically, the inferences considered during this integration include the human relevance of the animal and mechanistic evidence, coherence across the separate bodies of evidence, and other important information (e.g., judgments regarding susceptibility). Note that without evidence to the contrary, the human relevance of animal findings is assumed.
- A summary judgment is drawn as to whether the available evidence base for each potential human health effect as a whole provides sufficient evidence to indicate that Cr(VI) exposure has the potential to cause the health effect in humans; insufficient evidence to assess whether Cr(VI) exposure has the potential to cause the health effect in humans; or, in rare instances, sufficient evidence that a hazard is unlikely.

The decision points within the structured evidence integration process are summarized in an evidence profile table for each assessed health effect.

The primary focus of this assessment is on the following potential target systems: respiratory, gastrointestinal (GI) tract, hepatic, hematological, immunological, reproductive, and developmental. It is acknowledged that there is evidence for other health effects not assessed here, including renal and neurological toxicity, which can be induced by toxic metals in general (Fowler and Sexton, 2015). Kidney effects are known to occur following acute exposures to high doses or concentrations of Cr(VI) (ATSDR, 2012), but these effects are not observed following chronic, low-dose exposure. Neurotoxicity associated with Cr(VI) exposure has recently been reviewed by Wise et al. (2022); however, the evidence base is still relatively small and more research is needed in this area. Many studies of chromium and neurotoxicity would not meet PECO criteria due to lack of exposure information (e.g., studies of unspeciated chromium in organs and tissues of humans would be excluded) or focus on non-PECO chromium compounds (e.g., lead chromate). In addition, some endpoints would be difficult to dissociate from one another (e.g., impaired olfactory function and nasal effects).

For cancer and nasal irritation via the inhalation route, the systematic review will focus on data that may improve the quantitative dose-response analysis, conducted in EPA’s 1998 IRIS assessment, for these outcomes. Outlines of the major endpoints assessed within each health effect domain are listed below in Table 1-4.

Table 1-4 Endpoint grouping categories

Relevant human health effect category^a^ | Endpoints included^b^ | Notes
General toxicity | - Body weight (not maternal or pup weights, or weights after developmental-only exposure); - Mortality, survival, or LD_50_s; - Growth curve; - Clinical observations (non-behavioral) | - Clinical chemistry endpoints are under hepatic or hematologic effects; - Maternal or pup body-weight endpoints are under developmental effects; - Pathology (including gross lesions) is organ specific
Hepatic effects | - Liver weight and histopathology (e.g., chronic inflammation, hyperplasia); - Serum or tissue liver enzymes (e.g., clinical chemistry measures such as ALT, ALP, and AST)*; - Other liver tissue biochemical markers (e.g., albumin; glycogen; glucose)*; - Liver-specific serum biochemistry (e.g., albumin; albumin/globulin)*; - Liver tissue lipids: triglycerides, cholesterol; - Serum lipids | - Other liver tissue enzyme activity (e.g., catalase) or protein/DNA content are considered under mechanistic evidence for hepatic effects
Hematological effects | - Red blood cells*; - Blood hematocrit or hemoglobin*; - Cell volume*; - Blood platelets or reticulocytes* | - White blood cell count and globulin are under immune effects; - Serum liver markers are under hepatic effects
Immune effects | - Thymus weight and histopathology; - Host resistance; - General immune assays (e.g., white blood cell counts, immunological factors or cytokines in blood, lymphocyte phenotyping or proliferation)*; - Any measure in lymphoid tissues (weight; histopathology; cell counts; etc.); - Immune cell counts or immune-specific cytokines in non-lymphoid tissues; - Other immune functional assays (e.g., natural killer cell activity, mixed lymphocyte response, phagocytosis, or bacterial killing by monocytes); - Immune responses in the respiratory system | - Red blood cells are under hematological effects; - Immune responses in the respiratory tract (such as phagocytosis, cytokine signaling, inflammatory responses) are also under respiratory effects; - Endpoints related to Cr(VI)-induced allergic hypersensitivity were considered under mechanistic evidence for immune effects
Male Reproductive effects | - Reproductive organ weight and histopathology; - Markers of sexual differentiation or maturation (e.g., preputial separation); - Mating parameters (e.g., success, mount latency); - Reproductive hormones*; - Sperm and semen parameters* | - Birth parameters (e.g., litter size; resorptions, implantations, viability) are under developmental effects; - If data indicate altered birth parameters are likely attributable to female fertility, these data may be discussed under female reproductive effects
Female Reproductive effects | - Reproductive organ weight and histopathology; - Markers of sexual differentiation or maturation (e.g., vaginal opening or estrous cycling); - Birth parameters, if attributable to female fertility; - Reproductive hormones* | - Birth parameters (e.g., litter size; resorptions, implantations, viability) are under developmental effects
Developmental effects | - Dam health (e.g., weight gain, food consumption); - Pup viability/survival or other birth parameters (e.g., number of pups per litter); - Pup weight or growth (includes measures into adulthood after developmental-only exposure); - Developmental landmarks (eye opening, etc., but not including markers for other organ/system-specific toxicities); - Pregnancy outcomes (e.g., spontaneous abortion, early pregnancy loss, pregnancy complications, infant health, congenital malformations/anomalies) [human only] | - Histopathology and markers of development specific to other systems are organ/system-specific (e.g., vaginal opening is under female reproductive effects; offspring liver weight is under hepatic effects)
Lower respiratory effects; Note: Systematic review of evidence for nasal irritation via the inhalation route will focus on data for quantitative dose-response analysis. | - Lung weight and histopathology; - Biochemical markers of cell industry (e.g., total protein, albumin, and lactate dehydrogenase activity in bronchioalveolar lavage fluid); - Cellular responses (e.g., number of macrophages, neutrophils/granulocytes, and lymphocytes); - Pulmonary function (e.g., FVC, FEV1.0, DLCO) [human only] | - Immune responses in the respiratory tract (such as phagocytosis, cytokine signaling, inflammatory responses) are also under immune effects
Gastrointestinal tract effects | - Histopathology (e.g., chronic inflammation, hyperplasia, ulceration) | - Endpoints related to precancerous legions are also considered under carcinogenicity
Carcinogenicity; Note: Systematic review of evidence for cancer via the inhalation route will focus on data for quantitative dose-response analysis. | - Tumors; - Precancerous lesions (e.g., dysplasia)

ALT = alanine aminotransferase; AST = aspartate transaminase; DNA = deoxyribonucleic acid; LD50 = median lethal dose; FVC: forced vital capacity; FEV1.0: forced expiratory volume in first second; DLCO: diffusing capacity of lung for carbon monoxide.

a Health effect-relevant endpoints observed after developmental exposure will be discussed primarily in the health effect category indicated and then referenced in developmental effects.

b Endpoints refer to animal data unless otherwise noted. An asterisk (*) indicates endpoints that are also measured in humans. Endpoints that are only measured in humans are noted by descriptive text. Some endpoints are relevant to multiple health effects. These endpoints may be categorized under only a single health effect for clarity. However, in the assessment, such outcome data may be discussed in each relevant health effect synthesis, with cross-referencing to the synthesis containing most of the evidence. The evidence (for or against an effect) will contribute to evidence integration decisions for all relevant health effects.

### 1.2.5 Dose-Response Analysis

Dose-response analysis to support derivation of toxicity values for Cr(VI) were performed consistent with EPA guidelines and support documents, especially EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012b), EPA’s Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002), Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), and Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b). Section 11 of the Protocol (see Appendix A) describes the general approach to dose-response analysis used in this assessment.

This assessment includes development of a reference dose (RfD), a reference concentration (RfC), an inhalation unit risk (IUR), and an oral slope factor (OSF). From among the body of evidence used for the hazard identification assessment, selection of the studies for dose-response assessment used information from the study confidence evaluations, with particular emphasis on conclusions regarding the characteristics of the study population, the accuracy of the exposure estimates for epidemiology studies or dosing methods for toxicology studies, the severity of the observed effects, and the exposure levels analyzed (see Table 11-1 in U.S. EPA (2020b)).

When suitable data are available, as described in U.S. EPA (2020b), toxicity values should always be developed for evidence integration conclusions of evidence demonstrates and evidence indicates (likely) as well as for carcinogenicity descriptors of carcinogenic to humans or likely to be carcinogenic to humans. In general, toxicity values would not be developed for “evidence suggests” for noncancer hazard or “suggestive evidence of carcinogenic potential” for cancer hazard conclusions, respectively.

Additional special considerations were made when selecting studies for dose-response for Cr(VI), and these are discussed in greater detail in Section 4:

- Oral animal studies that did not include an exposed group below 20 mg/kg-day were not considered for quantitative analysis.^8^
- Inhalation animal studies that did not report measures of particle size and distribution were not considered for quantitative analysis.^9^
- Human studies for nasal cavity effects that did not report clinical outcomes diagnosed by a trained examiner (e.g., physician, otolaryngologist, or trained researcher) were not considered for quantitative analysis. The preferred clinical outcome measures were atrophy of the nasal mucosa; ulceration of the nasal mucosa or septum; perforation of the septum; and bleeding nasal septum.

1 In many studies, the administered compound is stated as “sodium dichromate” (Na_2_Cr_2_O_7_) when the compound is administered in aqueous solution with mass units based on sodium dichromate dihydrate (Na_2_Cr_2_O_7_ 2H_2_O). Unless otherwise noted, the conversion factor for sodium dichromate dihydrate (0.349) was used to convert parent compound concentrations and doses to Cr(VI) units for studies labeled as either sodium dichromate or sodium dichromate dihydrate. Because of variations in reporting, it may be unclear whether the mass per unit volume of the formulation was based on Na_2_Cr_2_O_7_ 2H_2_O or Na_2_Cr_2_O_7_ (which would yield a conversion factor of 0.397). In situations where the formulation was prepared based on units of Na_2_Cr_2_O_7_ mass, doses and concentrations listed in this assessment would underestimate the dose by 12%.

2 Cr(VI) was among 30 contaminants selected for monitoring at public water systems (PWS) for the Third Unregulated Contaminant Monitoring Rule (UCMR3) between 2013 and 2015. A PWS is a network of pipes and conveyances constructed to provide water for human consumption (U.S. EPA, 2006a, b). Small systems, serving 10,000 or fewer people, account for more than 97% of the total number of PWSs, while large systems, serving more than 10,000 people, account for the remaining 3% (U.S. EPA, 2006a, b). A majority of the U.S. population is served by large PWSs (nearly 90% (U.S. EPA, 2006a, b)), and all of them (approximately 4,200) were tested under UCMR3. For small water systems, approximately 800 systems were randomly selected and used as a representative sample (U.S. EPA, 2012c). Small water systems were omitted from analyses presented in this section. Cr(VI) was selected for the UCMR3 cycle and was not selected for monitoring for the UCMR4 or UCMR5 cycles.

3 See also: https://cfpub.epa.gov/roe/indicator.cfm?i=90#7, containing 2008–2014 data from 14 sites across the United States.

4 Region 1 - CT, ME, MA, NH, RI, and VT

Region 2 - NJ, NY, Puerto Rico, and the U.S. Virgin Islands

Region 3 - DE, DC, MD, PA, VA, WV and 7 federally recognized tribes

Region 4 - AL, FL, GA, KY, MS, NC, SC, and TN

Region 5 - IL, IN, MI, MN, OH, and WI

Region 6 - AR, LA, NM, OK, and TX

Region 7 - IA, KS, MO, and NE

Region 8 - CO, MT, ND, SD, UT, and WY

Region 9 - AZ, CA, HI, NV, American Samoa, Commonwealth of the Northern Mariana Islands, Federated States of Micronesia, Guam, Marshall Islands, and Republic of Palau

Region 10 - AK, ID, OR, WA and 271 native tribes.

5 Adequate intakes of chromium for adult males and females are 35 μg/day and 25 μg/day, respectively.

6 TOXLINE was phased out in December 2019 and integrated into other NLM resources.

7 Health and Environmental Research Online: https://hero.epa.gov/hero/.

8 A similar exposure consideration was not necessary for inhalation studies. Fewer animal inhalation studies were available, and concentrations were below levels that would cause severe toxicity.

9 Availability of particle size distribution information for each study is provided in HAWC.