# REFERENCES

Aaseth, J; Alexander, J; Norseth, T. (1982). Uptake of 51Cr-chromate by human erythrocytes - a role of glutathione. Acta Pharmacol Toxicol 50: 310–315. 10.1111/j.1600-0773.1982.tb00979.x.
Abreu, PL; Cunha-Oliveira, T; Ferreira, LMR; Urbano, AM. (2018). Hexavalent chromium, a lung carcinogen, confers resistance to thermal stress and interferes with heat shock protein expression in human bronchial epithelial cells. Biometals. 10.1007/s10534-018-0093-7.
ACGIH (American Conference of Governmental Industrial Hygienists). (2017). Draft summary: Chromium and inorganic compounds [TLV/BEI].
Acharya, UR; Mishra, M; Mishra, I. (2004a). Status of antioxidant defense system in chromium-induced Swiss mice tissues. Environ Toxicol Pharmacol 17: 117–123. 10.1016/j.etap.2004.02.005.21782722
Acharya, UR; Mishra, M; Mishra, I; Tripathy, RR. (2004b). Potential role of vitamins in chromium induced spermatogenesis in Swiss mice. Environ Toxicol Pharmacol 15: 53–59. 10.1016/j.etap.2003.08.010.21782680
Acharya, UR; Mishra, M; Tripathy, RR; Mishra, I. (2006). Testicular dysfunction and antioxidative defense system of Swiss mice after chromic acid exposure. Reprod Toxicol 22: 87–91. 10.1016/j.reprotox.2005.11.004.16434167
Adam, C; Wohlfarth, J; Haußmann, M; Sennefelder, H; Rodin, A; Maler, M; Martin, SF; Goebeler, M; Schmidt, M. (2017). Allergy-Inducing Chromium Compounds Trigger Potent Innate Immune Stimulation Via ROS-Dependent Inflammasome Activation. J Invest Dermatol 137: 367–376. 10.1016/j.jid.2016.10.003.27751866
Adams, SP; Laws, GM; Storer, RD; Deluca, JG; Nichols, WW. (1996). Detection of DNA damage induced by human carcinogens in acellular assays: potential application for determining genotoxic mechanisms. Mutat Res 368: 235–248.8692229
AEI (Applied Epidemiology Inc). (2002). Collaborative cohort mortality study of four chromate production facilities, 1958–1998: Final report. (8EHQ-0810–18050; OSHA Docket H054A Ex. 48–1–2). Pittsburgh, PA: Industrial Health Foundation. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0602411.xhtml.
Afolaranmi, GA; Grant, MH. (2013). The effect of ascorbic acid on the distribution of soluble Cr and Co ions in the blood and organs of rats. J Appl Toxicol 33: 220–226. 10.1002/jat.1744.22025242
Afolaranmi, GA; Tettey, JNA; Murray, HM; Meek, RMD; Grant, MH. (2010). The effect of anticoagulants on the distribution of chromium VI in blood fractions. J Arthroplasty 25: 118–120. 10.1016/j.arth.2008.10.012.
Ahmad, MK; Syma, S; Mahmood, R. (2011). Cr(VI) Induces Lipid Peroxidation, Protein Oxidation and Alters the Activities of Antioxidant Enzymes in Human Erythrocytes. Biol Trace Elem Res 144: 426–435. 10.1007/s12011-011-9119-5.21681464
Ahn, YS; Jeong, KS. (2014). Epidemiologic characteristics of compensated occupational lung cancers among Korean workers. J Korean Med Sci 29: 1473–1481. 10.3346/jkms.2014.29.11.1473.25408577
Ahn, YS; Park, RM; Stayner, L; Kang, SK; Jang, JK. (2006). Cancer morbidity in iron and steel workers in Korea. Am J Ind Med 49: 647–657. 10.1002/ajim.20337.16804912
Aiyar, J; Berkovits, HJ; Floyd, RA; Wetterhahn, KE. (1990). REACTION OF CHROMIUM(VI) WITH HYDROGEN PEROXIDE IN THE PRESENCE OF GLUTATHIONE: REACTIVE INTERMEDIATES AND RESULTING DNA DAMAGE. Chem Res Toxicol 595: 595–603. 10.1021/tx00018a016.
Aiyar, J; Berkovits, HJ; Floyd, RA; Wetterhahn, KE. (1991). Reaction of chromium(VI) with glutathione or with hydrogen peroxide: identification of reactive intermediates and their role in chromium(VI)-induced DNA damage. Environ Health Perspect 92: 53–62. 10.2307/3431137.1657590
Aiyar, J; Borges, K; Floyd, R; Wetterhahn, K. (1989). Role of chromium(V), glutathione thiyl radical and hydroxyl radical intermediates in Chromium(VI)-induced DNA Damage. Toxicol Environ Chem 22: 135–148. 10.1080/02772248909357432.
Aiyar, J; Deflora, S; Wetterhahn, KE. (1992). Reduction of chromium(VI) to chromium(V) by rat liver cytosolic and microsomal fractions: is DT-diaphorase involved. Carcinogenesis 13: 1159–1166.1379126
Akbar, M; Brewer, JM; Grant, MH. (2011). Effect of chromium and cobalt ions on primary human lymphocytes in vitro. J Immunotoxicol 8: 140–149. 10.3109/1547691X.2011.553845.21446789
Alderson, MR; Rattan, NS; Bidstrup, L. (1981). Health of workmen in the chromate-producing industry in Britain. Occup Environ Med 38: 117–124.
Alexander, BH; Checkoway, H; Wechsler, L; Heyer, NJ; Muhm, JM; O'Keeffe, TP. (1996). Lung cancer in chromate-exposed aerospace workers. J Occup Environ Med 38: 1253–1258. 10.1097/00043764-199612000-00011.8978517
Alexander, J; Aaseth, J. (1995). Uptake of chromate in human red blood cells and isolated rat liver cells: the role of the anion carrier. Analyst 120: 931–933. 10.1039/AN9952000931.7741257
Alexander, J; Aaseth, J; Norseth, T. (1982). Uptake of chromium by rat liver mitochondria. Toxicology 24: 115–122. 10.1016/0300-483X(82)90050-6.7135409
Alexander, J; Mikalsen, A; Ryberg, D. (1986). Microsomal reduction of Cr VI. Acta Pharmacol Toxicol 59: 267–269. 10.1111/j.1600-0773.1986.tb02759.x.
Alexopoulos, EC; Cominos, X; Trougakos, IP; Lourda, M; Gonos, ES; Makropoulos, V. (2008). Biological monitoring of hexavalent chromium and serum levels of the senescence biomarker Apolipoprotein J/Clusterin in welders. Bioinorganic Chemistry and Applications 2008: 420578. 10.1155/2008/420578.18464919
Alguacil, J; Porta, M; Kauppinen, T; Malats, N; Kogevinas, M; Carrato, A; Grp, PIS. (2003). Occupational exposure to dyes, metals, polycyclic aromatic hydrocarbons and other agents and K-ras activation in human exocrine pancreatic cancer. Int J Cancer 107: 635–641. 10.1002/ijc.11431.14520703
Ali, AH; Kondo, K; Namura, T; Senba, Y; Takizawa, H; Nakagawa, Y; Toba, H; Kenzaki, K; Sakiyama, S; Tangoku, A. (2011). Aberrant DNA methylation of some tumor suppressor genes in lung cancers from workers with chromate exposure. Mol Carcinog 50: 89–99. 10.1002/mc.20697.21229606
Alimba, CG; Dhillon, V; Bakare, AA; Fenech, M. (2016). Genotoxicity and cytotoxicity of chromium, copper, manganese and lead, and their mixture in WIL2-NS human B lymphoblastoid cells is enhanced by folate depletion. Mutat Res Genet Toxicol Environ Mutagen 798-799: 35–47. 10.1016/j.mrgentox.2016.02.002.
Amandus, HE. (1986). Mortality from stomach cancer in United States cement plant and quarry workers, 1950–80. Br J Ind Med 43: 526–528. 10.1136/oem.43.8.526.3637114
Andersen, A; Barlow, L; Engeland, A; Kjaerheim, K; Lynge, E; Pukkala, E. (1999). Work-related cancer in the Nordic countries [Supplemental Data]. Scand J Work Environ Health 25: 1–116.
Andersson, E; Persson, B; Bryngelsson, IL; Magnuson, A; Westberg, H. (2010). Cancer mortality in a Swedish cohort of pulp and paper mill workers. Int Arch Occup Environ Health 83: 123–132. 10.1007/s00420-009-0446-1.19636585
Andjelkovich, DA; Mathew, RM; Yu, RC; Richardson, RB; Levine, RJ. (1992). Mortality of iron foundry workers: II Analysis by work area. J Occup Environ Med 34: 391–401.
Andrew, AS; Warren, AJ; Barchowsky, A; Temple, KA; Klei, L; Soucy, NV; O'Hara, KA; Hamilton, JW. (2003). Genomic and proteomic profiling of responses to toxic metals in human lung cells. Environ Health Perspect 111: 825–835. 10.1289/txg.6249.12760830
Antonini, JM; Roberts, JR; Chapman, RS; Soukup, JM; Ghio, AJ; Sriram, K. (2010). Pulmonary toxicity and extrapulmonary tissue distribution of metals after repeated exposure to different welding fumes. Inhal Toxicol 22: 805–816. 10.3109/08958371003621641.20560776
Antonios, D; Ade, N; Kerdine-Römer, S; Assaf-Vandecasteele, H; Larangé, A; Azouri, H; Pallardy, M. (2009). Metallic haptens induce differential phenotype of human dendritic cells through activation of mitogen-activated protein kinase and NF-kappaB pathways. Toxicol In Vitro 23: 227–234. 10.1016/j.tiv.2008.11.009.19101624
Aoki, Y; Matsumoto, M; Matsumoto, M; Masumura, K; Nohmi, T. (2019). Mutant frequency is not increased in mice orally exposed to sodium dichromate. Food Saf 7: 2–10. 10.14252/foodsafetyfscj.2018014.
Aragones, N; Pollan, M; Gustavsson, P. (2002). Stomach cancer and occupation in Sweden: 1971–89. Occup Environ Med 59: 329–337. 10.1136/oem.59.5.329.11983848
Arakawa, H; Ahmad, R; Naoui, M; Tajmir-Riahi, HA. (2000). A comparative study of calf thymus DNA binding to Cr(III) and Cr(VI) ions. Evidence for the guanine N-7-chromium-phosphate chelate formation. J Biol Chem 275: 10150–10153.10744697
Arakawa, H; Weng, MW; Chen, WC; Tang, MS. (2012). Chromium (VI) induces both bulky DNA adducts and oxidative DNA damage at adenines and guanines in the p53 gene of human lung cells. Carcinogenesis 33: 1993–2000. 10.1093/carcin/bgs237.22791815
Arakawa, H; Wu, F; Costa, M; Rom, W; Tang, MS. (2006). Sequence specificity of Cr(III)-DNA adduct formation in the p53 gene: NGG sequences are preferential adduct-forming sites. Carcinogenesis 27: 639–645. 10.1093/carcin/bgi249.16251206
Arillo, A; Melodia, F; Frache, R. (1987). Reduction of Hexavalent Chromium by Mitochondria: Methodological Implications and Possible Mechanisms. Ecotoxicol Environ Saf 14: 164–177.3691371
Arlauskas, A; Baker, RSU; Bonin, AM; Tandon, RK; Crisp, PT; Ellis, J. (1985). Mutagenicity of metal ions in bacteria. Environ Res 36: 379–388. 10.1016/0013-9351(85)90032-5.3884331
Armienta-Hernández, MA; Rodríguez-Castillo, R. (1995). Environmental exposure to chromium compounds in the valley of León, México. Environ Health Perspect 103 Suppl 1: 47–51.
Arshad, M; Ahmad, N; Khalid, M; Asmatullah; Tahir, M; Naveed, K; Iqbal, A. (2017). Exposure of pregnant mice to hexavalent chromium causes fetal defects. Pakistan J Zool 49: 1383–1389. 10.17582/journal.pjz/2017.49.4.1383.1389.
Arslan, P; Beltrame, M; Tomasi, A. (1987). Intracellular chromium reduction. Biochim Biophys Acta 931: 10–15. 10.1016/0167-4889(87)90044-9.2820507
Aruldhas, MM; Subramanian, S; Sekar, P; Vengatesh, G; Chandrahasan, G; Govindarajulu, P; Akbarsha, MA. (2005). Chronic chromium exposure-induced changes in testicular histoarchitecture are associated with oxidative stress: study in a non-human primate (Macaca radiata Geoffroy). Hum Reprod 20: 2801–2813. 10.1093/humrep/dei148.15980013
Asatiani, N; Abuladze, M; Kartvelishvili, T; Kulikova, N; Asanishvili, L; Holman, HY; Sapojnikova, N. (2010). Response of antioxidant defense system to chromium (VI)-induced cytotoxicity in human diploid cells. Biometals 23: 161–172. 10.1007/s10534-009-9276-6.19915997
Asatiani, N; Kartvelishvili, T; Abuladze, M; Asanishvili, L; Sapojnikova, N. (2011). Chromium (VI) can activate and impair antioxidant defense system. Biol Trace Elem Res 142: 388–397. 10.1007/s12011-010-8806-y.20809274
Asatiani, N; Sapojnikova, N; Abuladze, M; Kartvelishvili, T; Kulikova, N; Kiziria, E; Namchevadze, E; Holman, HY. (2004). Effects of Cr(VI) long-term and low-dose action on mammalian antioxidant enzymes (an in vitro study). J Inorg Biochem 98: 490–496. 10.1016/j.jinorgbio.2003.12.014.14987850
Asgharian, B. (2004). A model of deposition of hygroscopic particles in the human lung. Aerosol Sci Technol 38: 938–947. 10.1080/027868290511236.
ATSDR (Agency for Toxic Substances and Disease Registry). (2012). Toxicological profile for chromium. Atlanta, GA: US Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=62&tid=17.
ATSDR (Agency for Toxic Substances and Disease Registry). (2016). Review and analysis of volatile organic compounds (VOCs) and metal exposures in air as part of the Midlothian Area Air Quality Petition Response Midlothian, Ellis County, Texas November 17, 2016. Atlanta, GA: U.S. Department of Health and Human Services.
Augspurger, T; Di Giulio, RT; Dorman, D; Kenyon, E; Howard, D; Starr, T; Stoskopf, M; Vandenberg, J; Tilson, B; Aneja, V. (2020). Secretaries' Science Advisory Board Response To Inquiry On Hexavalent Chromium. Available online at https://files.nc.gov/ncdeq/sab/20201127-Proposed-Final-Draft-SSAB-Memorandum-to-Secretaries-on-Hexavalent-Chromium.pdf (accessed November 15, 2023).
Awogi, T; Murata, K; Uejima, M; Kuwahara, T; Asanami, S; Shimono, K; Morita, T. (1992). Induction of micronucleated reticulocytes by potassium bromate and potassium chromate in CD-1 male mice. Mutat Res 278: 181–185.1372703
Axelsson, G; Rylander, R; Schmidt, A. (1980). Mortality and incidence of tumours among ferrochromium workers. Occup Environ Med 37: 121–127.
Azad, N; Iyer, AK; Manosroi, A; Wang, L; Rojanasakul, Y. (2008). Superoxide-mediated proteasomal degradation of Bcl-2 determines cell susceptibility to Cr(VI)-induced apoptosis. Carcinogenesis 29: 1538–1545. 10.1093/carcin/bgn137.18544562
Badding, MA; Fix, NR; Antonini, JM; Leonard, SS. (2014). A Comparison of Cytotoxicity and Oxidative Stress from Welding Fumes Generated with a New Nickel-, Copper-Based Consumable versus Mild and Stainless Steel-Based Welding in RAW 264.7 Mouse Macrophages. PLoS ONE 9: e101310. 10.1371/journal.pone.0101310.24977413
Bae, D; Camilli, TC; Chun, G; Lal, M; Wright, K; O'Brien, TJ; Patierno, S. R.; Ceryak, S. (2009a). Bypass of hexavalent chromium-induced growth arrest by a protein tyrosine phosphatase inhibitor: Enhanced survival and mutagenesis. Mutat Res Fundam Mol Mech Mutagen 660: 40–46. 10.1016/j.mrfmmm.2008.10.006.
Bae, D; Camilli, TC; Ha, NT; Ceryak, S. (2009b). Enhanced clonogenic survival induced by protein tyrosine phosphatase (PTP) inhibition after Cr(VI) exposure is mediated by c-Raf and Ras activity. Cell Signal 21: 727–736. 10.1016/j.cellsig.2009.01.011.19167484
Bagchi, D; Bagchi, M; Stohs, SJ. (2001). Chromium (VI)-induced oxidative stress, apoptotic cell death and modulation of p53 tumor suppressor gene. Mol Cell Biochem 222: 149–158. 10.1023/A:1017958028256.11678597
Bagchi, D; Bagchi, M; Tang, L; Stohs, SJ. (1997a). Comparative in vitro and in vivo protein kinase C activation by selected pesticides and transition metal salts. Toxicol Lett 91: 31–37.9096284
Bagchi, D; Balmoori, J; Bagchi, M; Ye, X; Williams, CB; Stohs, SJ. (2000a). Role of p53 tumor suppressor gene in the toxicity of TCDD, endrin, naphthalene, and chromium (VI) in liver and brain tissues of mice. Free Radic Biol Med 28: 895–903. 10.1016/S0891-5849(00)00173-8.10802220
Bagchi, D; Balmoori, J; Bagchi, M; Ye, X; Williams, CB; Stohs, SJ. (2002a). Comparative effects of TCDD, endrin, naphthalene and chromium (VI) on oxidative stress and tissue damage in the liver and brain tissues of mice. Toxicology 175: 73–82. 10.1016/S0300-483X(02)00062-8.12049837
Bagchi, D; Hassoun, EA; Bagchi, M; Muldoon, DF; Stohs, SJ. (1995a). Oxidative stress induced by chronic administration of sodium dichromate [Cr(VI)] to rats. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 110: 281–287. 10.1016/0742-8413(94)00103-H.7599977
Bagchi, D; Hassoun, EA; Bagchi, M; Stohs, SJ. (1995b). Chromium-induced excretion of urinary lipid metabolites, DNA damage, nitric oxide production, and generation of reactive oxygen species in Sprague-Dawley rats. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 110: 177–187. 10.1016/0742-8413(94)00093-P.7599967
Bagchi, D; Joshi, SS; Bagchi, M; Balmoori, J; Benner, EJ; Kuszynski, CA; Stohs, SJ. (2000b). Cadmium-and chromium-induced oxidative stress, DNA damage, and apoptotic cell death in cultured human chronic myelogenous leukemic K562 cells, promyelocytic leukemic HL-60 cells, and normal human peripheral blood mononuclear cells. J Biochem Mol Toxicol 14: 33–41.10561080
Bagchi, D; Stohs, SJ; Downs, BW; Bagchi, M; Preuss, HG. (2002b). Cytotoxicity and oxidative mechanisms of different forms of chromium. Toxicology 180: 5–22.12324196
Bagchi, D; Vuchetich, PJ; Bagchi, M; Hassoun, EA; Tran, MX; Tang, L; Stohs, SJ. (1997b). Induction of oxidative stress by chronic administration of sodium dichromate [chromium VI] and cadmium chloride [cadmium II] to rats. Free Radic Biol Med 22: 471–478. 10.1016/s0891-5849(96)00352-8.8981039
Bai, JPF; Burckart, GJ; Mulberg, AE. (2016). Literature review of gastrointestinal physiology in the elderly, in pediatric patients, and in patients with gastrointestinal diseases [Review]. J Pharm Sci 105: 476–483. 10.1002/jps.24696.26539698
Balachandar, V; Arun, M; Mohana Devi, S; Velmurugan, P; Manikantan, P; Karthick Kumar, A; Sasikala, K; Venkatesan, C. (2010). Evaluation of the genetic alterations in direct and indirect exposures of hexavalent chromium [Cr(VI)] in leather tanning industry workers North Arcot District, South India. Int Arch Occup Environ Health 83: 791–801. 10.1007/s00420-010-0562-y.20617332
Balakin, VM; Sukhacheva, EI; Buryndin, VG; Masna, VM; Semenov, DI. (1981). Synthesis and study of the effect of oligomeric quaternary salts on the excretion and resorption of hexavalent chromium from the rat organism. Pharmaceutical Chemistry Journal 15: 712–715.
Ban, M; Langonné, I; Goutet, M; Huguet, N; Pépin, E. (2010). Simultaneous analysis of the local and systemic immune responses in mice to study the occupational asthma mechanisms induced by chromium and platinum. Toxicology 277: 29–37. 10.1016/j.tox.2010.08.010.20732381
Banu, SK; Samuel, JB; Arosh, JA; Burghardt, RC; Aruldhas, MM. (2008). Lactational exposure to hexavalent chromium delays puberty by impairing ovarian development, steroidogenesis and pituitary hormone synthesis in developing Wistar rats. Toxicol Appl Pharmacol 232: 180–189. 10.1016/j.taap.2008.06.002.18602937
Banu, SK; Stanley, JA; Lee, J; Stephen, SD; Arosh, JA; Hoyer, PB; Burghardt, RC. (2011). Hexavalent chromium-induced apoptosis of granulosa cells involves selective sub-cellular translocation of Bcl-2 members, ERK1/2 and p53. Toxicol Appl Pharmacol 251: 253–266. 10.1016/j.taap.2011.01.011.21262251
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Barhoumi, R; Burghardt, RC. (2015). Identifying a novel role for X-prolyl aminopeptidase (Xpnpep) 2 in CrVI-induced adverse effects on germ cell nest breakdown and follicle development in rats. Biol Reprod 92: 67. 10.1095/biolreprod.114.125708.25568306
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Burghardt, RC. (2016). Resveratrol protects the ovary against chromium-toxicity by enhancing endogenous antioxidant enzymes and inhibiting metabolic clearance of estradiol. Toxicol Appl Pharmacol 303: 65–78. 10.1016/j.taap.2016.04.016.27129868
Banu, SK; Stanley, JA; Sivakumar, KK; Arosh, JA; Taylor, RJ; Burghardt, RC. (2017a). Chromium VI -Induced developmental toxicity of placenta is mediated through spatiotemporal dysregulation of cell survival and apoptotic proteins. Reprod Toxicol 68: 171–190. 10.1016/j.reprotox.2016.07.006.27443218
Banu, SK; Stanley, JA; Sivakumar, KK; Taylor, RJ; Arosh, JA; Burghardt, RC. (2017b). Editor's highlight: Exposure to CrVI during early pregnancy increases oxidative stress and disrupts the expression of antioxidant proteins in placental compartments. Toxicol Sci 155: 497–511. 10.1093/toxsci/kfw231.28077780
Banu, SK; Stanley, JA; Taylor, RJ; Sivakumar, KK; Arosh, JA; Zeng, L; Pennathur, S; Padmanabhan, V. (2018). Sexually Dimorphic Impact of Chromium Accumulation on Human Placental Oxidative Stress and Apoptosis. Toxicol Sci 161: 375–387. 10.1093/toxsci/kfx224.29069462
Barchowsky, A. (2006). JNK activation by chromium in the lung [Abstract]. Toxicologist 90: 309.
Barraj, L; Scrafford, C; Lantz, J; Daniels, C; Mihlan, G. (2009). Within-day drinking water consumption patterns: results from a drinking water consumption survey. J Expo Sci Environ Epidemiol 19: 382–395. 10.1038/jes.2008.28.18478045
Bartholomäus, R; Irwin, JA; Shi, L; Smith, SM; Levina, A; Lay, PA. (2013). Isolation, characterization, and nuclease activity of biologically relevant chromium(V) complexes with monosaccharides and model diols. Likely intermediates in chromium-induced cancers. Inorg Chem 52: 4282–4292. 10.1021/ic3022408.23531300
Bashandy, SAE; Ebaid, H; Al-Tamimi, J; Ahmed-Farid, OA; Omara, EA; Alhazza, IM. (2021). Melatonin Alleviated Potassium Dichromate-Induced Oxidative Stress and Reprotoxicity in Male Rats. BioMed Res Int 2021: 3565360. 10.1155/2021/3565360.34222468
Beasley, DE; Koltz, AM; Lambert, JE; Fierer, N; Dunn, RR. (2015). The evolution of stomach acidity and its relevance to the human microbiome [Review]. PLoS ONE 10: e0134116. 10.1371/journal.pone.0134116.26222383
Becker, N. (1999). Cancer mortality among arc welders exposed to fumes containing chromium and nickel. Results of a third follow-up: 1989–1995. J Occup Environ Med 41: 294–303. 10.1097/00043764-199904000-00012.10224596
Becker, N; Changclaude, J; Frentzelbeyme, R. (1991). Risk of cancer for arc welders in the Federal Republic of Germany: results of a second follow up (1983–8). Br J Ind Med 48: 675–683. 10.1136/oem.48.10.675.1931726
Becker, N; Claude, J; Frentzel-Beyme, R. (1985). Cancer risk of arc welders exposed to fumes containing chromium and nickel. Scand J Work Environ Health 11: 75–82.
Behari, J; Chandra, SV; Tandon, SK. (1978). Comparative toxicity of trivalent and hexavalent chromium to rabbits III Biochemical and histological changes in testicular tissue. Biomed Biochim Acta 37: 463–468.
Behrens, T; Ge, C; Vermeulen, R; Kendzia, B; Olsson, A; Schüz, J; Kromhout, H; Pesch, B; Peters, S; Portengen, L; Gustavsson, P; Mirabelli, D; Guénel, P; Luce, D; Consonni, D; Caporaso, NE; Landi, MT; Field, JK; Karrasch, S; ... Brüning, T. (2023). Occupational exposure to nickel and hexavalent chromium and the risk of lung cancer in a pooled analysis of case-control studies (SYNERGY). Int J Cancer 152: 645–660. 10.1002/ijc.34272.36054442
Bennicelli, C; Camoirano, A; Petruzzelli, S; Zanacchi, P; De Flora, S. (1983). High sensitivity of Salmonella TA102 in detecting hexavalent chromium mutagenicity and its reversal by liver and lung preparations. Mutat Res 122: 1–5.6353220
Bennink, RJ; de Jonge, WJ; Symonds, EL; van den Wijngaard, RM; Spijkerboer, AL; Benninga, MA; Boeckxstaens, GE. (2003). Validation of gastric-emptying scintigraphy of solids and liquids in mice using dedicated animal pinhole scintigraphy. J Nucl Med 44: 1099–1104.12843228
Benova, D; Hadjidekova, V; Hristova, R; Nikolova, T; Boulanova, M; Georgieva, I; Grigorova, M; Popov, T; Panev, T; Georgieva, R; Natarajan, AT; Darroudi, F; Nilsson, R. (2002). Cytogenetic effects of hexavalent chromium in Bulgarian chromium platers. Mutat Res 514: 29–38.11815242
Berndt, WO. (1976). Renal chromium accumulation and its relationship to chromium-induced nephrotoxicity. J Toxicol Environ Health 1: 449–459. 10.1080/15287397609529344.1551
Bertazzi, PA; Zocchetti, C. (1980). A mortality study of newspaper printing workers. Am J Ind Med 1: 85–97.7342757
Bertram, J; Brand, P; Schettgen, T; Lenz, K; Purrio, E; Reisgen, U; Kraus, T. (2014). Human Biomonitoring of Chromium and Nickel from an Experimental Exposure to Manual Metal Arc Welding Fumes of Low and High Alloyed Steel. Ann Occup Hyg 59: 467–480. 10.1093/annhyg/meu104.25512666
Bethwaite, PB; Pearce, N; Fraser, J. (1990). Cancer risks in painters: study based on the New Zealand Cancer Registry. Br J Ind Med 47: 742–746. 10.1136/oem.47.11.742.2245185
Beveridge, R; Pintos, J; Parent, ME; Asselin, J; Siemiatycki, J. (2010). Lung cancer risk associated with occupational exposure to nickel, chromium VI, and cadmium in two population-based case-control studies in Montreal. Am J Ind Med 53: 476–485. 10.1002/ajim.20801.20187007
Beyersmann, D; Koster, A; Buttner, B; Flessel, P. (1984). Model reactions of chromium compounds with mammalian and bacterial cells. Toxicol Environ Chem 8: 279–286. 10.1080/02772248409357059.
Bhat, VS; Cohen, SM; Gordon, EB; Wood, CE; Cullen, JM; Harris, MA; Proctor, DM; Thompson, CM. (2020). An adverse outcome pathway for small intestinal tumors in mice involving chronic cytotoxicity and regenerative hyperplasia: A case study with hexavalent chromium, captan, and folpet [Review]. CRC Crit Rev Toxicol 50: 685–706. 10.1080/10408444.2020.1823934.
Bianchi, V; Celotti, L; Lanfranchi, G; Majone, F; Marin, G; Montaldi, A; Sponza, G; Tamino, G; Venier, P; Zantedeschi, A; Levis, AG. (1983). Genetic effects of chromium compounds. Mutat Res 117: 279–300.6343855
Bianchi, V; Dal TOSO, R; Debetto, P; Gino LEVIS, A; Luciani, S; Majone, F; Tamino, G. (1980). Mechanisms of chromium toxicity in mammalian cell cultures. Toxicology 219: 219–224.
Bidstrup, PL. (1951). Carcinoma of the lung in chromate workers. Occup Environ Med 8: 302–305.
Bidstrup, PL; Case, RAM. (1956). Carcinoma of the lung in workmen in the bichromates-producing industry in Great Britain. Occup Environ Med 13: 260–264.
Birk, T; Mundt, KA; Dell, LD; Luippold, RS; Miksche, L; Steinmann-Steiner-Haldenstaett, W; Mundt, DJ. (2006). Lung cancer mortality in the German chromate industry, 1958 to 1998. J Occup Environ Med 48: 426–433. 10.1097/01.jom.0000194159.88688.f8.16607199
Black, K; Gochfeld, M; Lioy, PJ; Fan, ZH; Yu, CH; Jeitner, C; Hernandez, M; Einstein, SA; Stern, AH. (2015). A post-remediation assessment in Jersey City of the association of hexavalent chromium in house dust and urinary chromium in children. J Expo Sci Environ Epidemiol 25: 616–622. 10.1038/jes.2015.50.26329141
Blair, A. (1980). Mortality among workers in the metal polishing and plating industry, 1951–1969. J Occup Med 22: 158–162.7365552
Blankenship, LJ; Carlisle, DL; Wise, JP, Sr; Orenstein, JM; LEIII, D; Patierno, S. R. (1997). Induction of apoptotic cell death by particulate lead chromate: differential effects of vitamins C and E on genotoxicity and survival. Toxicol Appl Pharmacol 146: 270–280. 10.1006/taap.1997.8237.9344895
Blasiak, J; Kowalik, J. (2000). A comparison of the in vitro genotoxicity of tri- and hexavalent chromium. Mutat Res 469: 135–145.10946250
Błasiak, J; Trzeciak, A; Małecka-Panas, E; Drzewoski, J; Iwanienko, T; Szumiel, I; Wojewódzka, M. (1999). DNA damage and repair in human lymphocytes and gastric mucosa cells exposed to chromium and curcumin. Teratog Carcinog Mutagen 19: 19–31. 10.1002/(SICI)1520-6866(1999)19:1-19::AID-TCM3>3.0.CO;2-H.10321407
Bloomfield, JJ; Blum, W. (1928). Health hazards in chromium plating. Public Health Rep 43: 527–528. 10.2307/4578958.
Blot, WJ; Fryzek, JP; Henderson, BE; Sadler, CJ; Mclaughlin, JK. (2000). A cohort mortality study among gas generator utility workers. J Occup Environ Med 42: 194–199.10693081
Boffetta, P; Autier, P; Boniol, M; Boyle, P; Hill, C; Aurengo, A; Masse, R; Thé, G; Valleron, AJ; Monier, R; Tubiana, M. (2010). An estimate of cancers attributable to occupational exposures in France. J Occup Environ Med 52: 399–406. 10.1097/JOM.0b013e3181d5e355.20357680
Boice, JD, Jr; Marano, D; Fryzek, J; Sadler, C; Mclaughlin, JK. (1999). Mortality among aircraft manufacturing workers. Occup Environ Med 56: 581–597. 10.1136/oem.56.9.581.10615290
Bonatti, S; Meini, M; Abbondandolo, A. (1976). Genetic effects of potassium dichromate in Schizosaccharomyces pombe. DNA Repair 38: 147–150.
Boobis, AR; Cohen, SM; Dellarco, V; McGregor, D; Meek, ME; Vickers, C; Willcocks, D; Farland, W. (2006). IPCS framework for analyzing the relevance of a cancer mode of action for humans. Crit Rev Toxicol 36: 781–792. 10.1080/10408440600977677.17118728
Boone, L; Meyer, D; Cusick, P; Ennulat, D; Bolliger, AP; Everds, N; Meador, V; Elliott, G; Honor, D; Bounous, D; Jordan, H. (2005). Selection and interpretation of clinical pathology indicators of hepatic injury in preclinical studies [Review]. Vet Clin Pathol 34: 182–188. 10.1111/j.1939-165X.2005.tb00041.x.16134065
Borella, P; Bargellini, A. (1993). Effects of trace elements on immune system: results in cultured human lymphocytes. J Trace Elem Med Biol 7: 231–233.
Borges, KM; Wetterhahn, KE. (1989). Chromium cross-links glutathione and cysteine to DNA. Carcinogenesis 10: 2165–2168. 10.1093/carcin/10.11.2165.2805236
Borthiry, GR; Antholine, WE; Kalyanaraman, B; Myers, JM; Myers, CR. (2007). Reduction of hexavalent chromium by human cytochrome b5: generation of hydroxyl radical and superoxide. Free Radic Biol Med 42: 738–755; discussion 735–737. 10.1016/j.freeradbiomed.2006.10.055.17320757
Borthiry, GR; Antholine, WE; Myers, JM; Myers, CR. (2008). Reductive activation of hexavalent chromium by human lung epithelial cells: Generation of Cr(V) and Cr(V)-thiol species. J Inorg Biochem 102: 1449–1462. 10.1016/j.jinorgbio.2007.12.030.18279960
Botta, A; Occhipinti, P; Bartfai, E; Orsiere, T. (1996). Genotoxic effects of potassium dichromate in cultural human lymphocytes. Med Sci Res 24: 797–799.
Bouchardy, C; Schüler, G; Minder, C; Hotz, P; Bousquet, A; Levi, F; Fisch, T; Torhorst, J; Raymond, L. (2002). Cancer risk by occupation and socioeconomic group among men--A study by the Association of Swiss Cancer Registries. Scand J Work Environ Health 28: 1–88.
Bourdon-Lacombe, JA; Moffat, ID; Deveau, M; Husain, M; Auerbach, S; Krewski, D; Thomas, RS; Bushel, PR; Williams, A; Yauk, CL. (2015). Technical guide for applications of gene expression profiling in human health risk assessment of environmental chemicals. Regul Toxicol Pharmacol 72: 292–309. 10.1016/j.yrtph.2015.04.010.25944780
Bovet, P; Lob, M; Grandjean, M. (1977). Spirometric alterations in workers in the chromium electroplating industry. Int Arch Occup Environ Health 40: 25–32. 10.1007/BF00435514.914372
Bragt, PC; van Dura, EA. (1983). Toxicokinetics of hexavalent chromium in the rat after intratracheal administration of chromates of different solubilities. Ann Occup Hyg 27: 315–322. 10.1093/annhyg/27.3.315.6638765
Brams, A; Buchet, JP; Crutzen-Fayt, MC; De Meester, C; Lauwerys, R; Leonard, A. (1987). A comparative study, with 40 chemicals, of the efficiency of the Salmonella assay and the SOS chromotest (kit procedure). Toxicol Lett 38: 123–133.3307023
Branca, M; Dessi, A; Kozlowski, H; Micera, G; Serra, MV. (1989). In vitro interaction of mutagenic chromium (VI) with red blood cells. FEBS Lett 257: 52–54.2553494
Braver, ER; Infante, P; Chu, K. (1985). An analysis of lung cancer risk from exposure to hexavalent chromium. Birth Defects Res B Dev Reprod Toxicol 5: 365–378.
Bravo, I; Carvalho, GS; Barbosa, MA; de Sousa, M. (1990). Differential effects of eight metal ions on lymphocyte differentiation antigens in vitro. J Biomed Mater Res 24: 1059–1068. 10.1002/jbm.820240808.2394762
Brazma, A; Hingamp, P; Quackenbush, J; Sherlock, G; Spellman, P; Stoeckert, C; Aach, J; Ansorge, W; Ball, CA; Causton, HC; Gaasterland, T; Glenisson, P; Holstege, FC; Kim, IF; Markowitz, V; Matese, JC; Parkinson, H; Robinson, A; Sarkans, U; Schulze-Kremer, S; Stewart, J; Taylor, R; Vilo, J; Vingron, M. (2001). Minimum information about a microarray experiment (MIAME)-toward standards for microarray data. Nat Genet 29: 365–371. 10.1038/ng1201-365.11726920
Bridgewater, LC; Manning, FC; Patierno, SR. (1998). Arrest of replication by mammalian DNA polymerases alpha and beta caused by chromium-DNA lesions. Mol Carcinog 23: 201–206.9869448
Bridgewater, LC; Manning, FC; Woo, ES; Patierno, SR. (1994). DNA polymerase arrest by adducted trivalent chromium. Mol Carcinog 9: 122–133. 10.1002/mc.2940090304.8142016
Briggs, JA; Briggs, RC. (1988). Characterization of chromium effects on a rat liver epithelial cell line and their relevance to in vitro transformation. Cancer Res 48: 6484–6490.3180065
Bronzetti, GL; Galli, A. (1989). Influence of NTA on the chromium genotoxicity. Toxicol Environ Chem 23: 101–104.
Brown, LM; Moradi, T; Gridley, G; Plato, N; Dosemeci, M; Fraumeni, JF. (2002). Exposures in the painting trades and paint manufacturing industry and risk of cancer among men and women in Sweden. J Occup Environ Med 44: 258–264. 10.1097/00043764-200203000-00013.11911027
Brown, RP; Delp, MD; Lindstedt, SL; Rhomberg, LR; Beliles, RP. (1997). Physiological parameter values for physiologically based pharmacokinetic models [Review]. Toxicol Ind Health 13: 407–484. 10.1177/074823379701300401.9249929
Brown, SC; Schonbeck, MF; Mcclure, D; Barón, AE; Navidi, WC; Byers, T; Ruttenber, AJ. (2004). Lung cancer and internal lung doses among plutonium workers at the Rocky Flats Plant: a case-control study. Am J Epidemiol 160: 163–172. 10.1093/aje/kwh192.15234938
Browning, CL; Qin, Q; Kelly, DF; Prakash, R; Vanoli, F; Jasin, M; Wise, JP. (2016). Prolonged Particulate Hexavalent Chromium Exposure Suppresses Homologous Recombination Repair in Human Lung Cells. Toxicol Sci 153: 70–78. 10.1093/toxsci/kfw103.27449664
Browning, CL; Wise, JP. (2017). Prolonged exposure to particulate chromate inhibits RAD51 nuclear import mediator proteins. Toxicol Appl Pharmacol 331: 101–107. 10.1016/j.taap.2017.05.030.28554658
Browning, J; Gannon, BJ; O'Brien, P. (1983). The microvasculature and gastric luminal pH of the forestomach of the rat: A comparison with the glandular stomach. Int J Microcirc Clin Exp 2: 109–118.6678841
Brownson, RC; Zahm, SH; Chang, JC; Blair, A. (1989). Occupational risk of colon cancer. An analysis by anatomic subsite. Am J Epidemiol 130: 675–687. 10.1093/oxfordjournals.aje.a115389.2773916
Bruno, M; Ross, J; Ge, Y. (2016). Proteomic responses of BEAS-2B cells to nontoxic and toxic chromium: Protein indicators of cytotoxicity conversion. Toxicol Lett 264: 59–70. 10.1016/j.toxlet.2016.08.025.27592090
Bryson, WG; Goodall, CM. (1983). Differential toxicity and clearance kinetics of chromium(III) or (VI) in mice. Carcinogenesis 4: 1535–1539.6652867
Bulbulyan, MA; Ilychova, SA; Zahm, SH; Astashevsky, SV; Zaridze, DG. (1999). Cancer mortality among women in the Russian printing industry. Am J Ind Med 36: 166–171. 10.1002/(SICI)1097-0274(199907)36:1<166::AID-AJIM24>3.0.CO;2-P.10361603
Bulikowski, W; Pietrzak, I; Borzecki, A; Lingas, W. (1999). Investigations on magnesium and chromium antagonism in the skin of experimental animals. Magnes Res 12: 115–121.10423706
Buttner, B; Beyersmann, D. (1985). Modification of the erythrocyte anion carrier by chromate. Xenobiotica 15: 735–741. 10.3109/00498258509047435.4072261
Buttner, B; Hebeler, M; Beyersmann, D. (1988). Chromate effects on human erythrocytes--investigations on sulphydryl groups, cross-linking of membrane proteins and electromechanical properties in the coulter-counter. Sci Total Environ 71: 555–560. 10.1016/0048-9697(88)90236-7.3406723
CA State Water Board (California State Water Quality Control Board). (2022). Frequently asked questions: Proposed maximum contaminant level (MCL) for hexavalent chromium. Sacramento, CA.
Caglieri, A; Goldoni, M; Acampa, O; Andreoli, R; Vettori, MV; Corradi, M; Apostoli, P; Mutti, A. (2006). The effect of inhaled chromium on different exhaled breath condensate biomarkers among chrome-plating workers. Environ Health Perspect 114: 542–546. 10.1289/ehp.8506.16581543
Caglieri, A; Goldoni, M; De Palma, G; Mozzoni, P; Gemma, S; Vichi, S; Testai, E; Panico, F; Corradi, M; Tagliaferri, S; Costa, LG. (2008). Exposure to low levels of hexavalent chromium: target doses and comparative effects on two human pulmonary cell lines. Acta Biomed 79 Suppl 1: 104–115.18924316
CalEPA (California Environmental Protection Agency). (2003). Ambient air monitoring for hexavalent chromium and metals in Barrio Logan: May 2001 through May 2002. (Report: 2003–10-14). Sacramento, CA.
CalEPA (California Environmental Protection Agency). (2004). Barrio Logan report: A compilation of air quality studies in Barrio Logan. November 2004. (Report: 2005–11-00). Sacramento, CA.
CalEPA (California Environmental Protection Agency). (2008). TSD for noncancer RELs - Appendix D.3 Chronic RELs and toxicity summaries using the previous version of the Hot Spots Risk Assessment guidelines (OEHHA 1999). Sacramento, CA: California Office of Environmental Health Hazard Assessment:: OEHHA. http://oehha.ca.gov/media/downloads/crnr/appendixd3final.pdf.
CalEPA (California Environmental Protection Agency). (2011). Public health goal for Hexavalent Chromium (Cr VI) in drinking water. Sacramento, CA: Pesticide and Environmental Toxicology Branch, Office of Environmental Health Hazard Assessment. http://oehha.ca.gov/media/downloads/water/public-health-goal/cr6phg072911.pdf.
Cammarota, M; Lamberti, M; Masella, L; Galletti, P; De Rosa, M; Sannolo, N; Giuliano, M. (2006). Matrix metalloproteinases and their inhibitors as biomarkers for metal toxicity in vitro. Toxicol In Vitro 20: 1125–1132. 10.1016/j.tiv.2006.02.004.16581223
Cao, X; Wang, S; Bi, R; Tian, S; Huo, Y; Liu, J. (2019). Toxic effects of Cr(VI) on the bovine hemoglobin and human vascular endothelial cells: Molecular interaction and cell damage. Chemosphere 222: 355–363. 10.1016/j.chemosphere.2019.01.137.30710761
Capellmann, M; Bolt, HM. (1992). Chromium (VI) reducing capacity of ascorbic acid and of human plasma in vitro. Arch Toxicol 66: 45–50. 10.1007/BF02307269.1580793
Capellmann, M; Mikalsen, A; Hindrum, M; Alexander, J. (1995). Influence of reducing compounds on the formation of DNA-protein cross-links in HL-60 cells induced by hexavalent chromium. Carcinogenesis 16: 1135–1139. 10.1093/carcin/16.5.1135.7767976
CARB (California Air Resources Board). (2006). Proposed amendments to the hexavalent chromium airborne toxic control measure for chrome plating and chromic acid anodizing operations. Sacramento, CA: California Environmental Protection Agency.
Carette, D; Perrard, MH; Prisant, N; Gilleron, J; Pointis, G; Segretain, D; Durand, P. (2013). Hexavalent chromium at low concentration alters Sertoli cell barrier and connexin 43 gap junction but not claudin-11 and N-cadherin in the rat seminiferous tubule culture model. Toxicol Appl Pharmacol 268: 27–36. 10.1016/j.taap.2013.01.016.23357549
Carlisle, DL; Pritchard, DE; Singh, J; Owens, BM; Blankenship, LJ; Orenstein, JM; Patierno, SR. (2000a). Apoptosis and P53 induction in human lung fibroblasts exposed to chromium (VI): Effect of ascorbate and tocopherol. Toxicol Sci 55: 60–68. 10.1093/toxsci/55.1.60.10788560
Carlisle, DL; Pritchard, DE; Singh, J; Patierno, SR. (2000b). Chromium(VI) induces p53-dependent apoptosis in diploid human lung and mouse dermal fibroblasts. Mol Carcinog 28: 111–118. 10.1002/1098-2744(200006)28:2<111::AID-MC7>3.0.CO;2-Y.10900468
Castorina, A; Tiralongo, A; Cavallo, D; Loreto, C; Carnazza, ML; Iavicoli, S; D'Agata, V. (2008). Expression profile of ErbB receptor's family in human alveolar type 2-like cell line A549 exposed to hexavalent chromium. Toxicol In Vitro 22: 541–547. 10.1016/j.tiv.2007.10.003.18053681
Cavalleri, A; Minoia, C; Richelmi, P; Baldi, C; Micoli, G. (1985). Determination of total and hexavalent chromium in bile after intravenous administration of potassium dichromate in rats. Environ Res 37: 490–496. 10.1016/0013-9351(85)90130-6.4017998
Cavallo, D; Ursini, CL; Fresegna, AM; Ciervo, A; Maiello, R; Rondinone, B; D'Agata, V; Iavicoli, S. (2010). Direct-oxidative DNA damage and apoptosis induction in different human respiratory cells exposed to low concentrations of sodium chromate. J Appl Toxicol 30: 218–225. 10.1002/jat.1487.19839025
CDHS (California Department of Health Services). (1985). Health Assessment for Chromium. Berkeley and Sacramento, CA: California Department of Health Services (later OEHHA, California Environmental Protection Agency).
CDPH (California Department of Public Health). (2013). Notice of proposed rulemaking: Title 22, California Code of Regulations subject: Hexavalent chromium mcl (DPH-11–005). Available online at (accessed
Ceballos, D; West, C; Methner, M; Gong, W. (2017). Health hazard evaluation report: HHE-2013–0011-3278, May 2017. Evaluation of chromium, hexavalent chromium, cadmium, and isocyanate exposures in an African refinishing plant. (HHE-2013–0011-3278). National Institute for Occupational Safety and Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2017102698.xhtml.
Ceballos, D; West, C; Methner, M; Gong, W. (2019). Hexavalent Chromium Exposure and Nasal Tissue Effects at a Commercial Aircraft Refinishing Facility. J Occup Environ Med 61: e69–e73. 10.1097/JOM.0000000000001510.30507787
Cena, LG; Chisholm, WP; Keane, MJ; Chen, BT. (2015). A Field Study on the Respiratory Deposition of the Nano-Sized Fraction of Mild and Stainless Steel Welding Fume Metals. J Occup Environ Hyg 12: 721–728. 10.1080/15459624.2015.1043055.25985454
Cerveira, JF; Sánchez-Aragó, M; Urbano, AM; Cuezva, JM. (2014). Short-term exposure of nontumorigenic human bronchial epithelial cells to carcinogenic chromium(VI) compromises their respiratory capacity and alters their bioenergetic signature. 4: 594–601. 10.1016/j.fob.2014.06.006.
Ceryak, S; Zingariello, C; O'Brien, T; Patierno, S. R. (2004). Induction of pro-apoptotic and cell cycle-inhibiting genes in chromium (VI)-treated human lung fibroblasts: Lack of effect of ERK. Mol Cell Biochem 255: 139–149. 10.1023/B:MCBI.0000007270.82431.3e.14971655
Chang, FH; Wang, SL; Huang, YL; Tsai, MH; Yu, ST; Chang, LW. (2006). Biomonitoring of chromium for residents of areas with a high density of electroplating factories. J Expo Sci Environ Epidemiol 16: 138–146. 10.1038/sj.jea.7500445.16106258
Chappell, GA; Rager, JE; Wolf, J; Babic, M; Leblanc, KJ; Ring, CL; Harris, MA; Thompson, CM. (2019). Comparison of Gene Expression Responses in the Small Intestine of Mice Following Exposure to 3 Carcinogens Using the S1500+ Gene Set Informs a Potential Common Adverse Outcome Pathway. Toxicol Pathol 47: 192623319873882. 10.1177/0192623319873882.
Chappell, GA; Wikoff, DS; Thompson, CM. (2021). Assessment of mechanistic data for hexavalent chromium-induced rodent intestinal cancer using the key characteristics of carcinogens. Toxicol Sci 180: 38–50. 10.1093/toxsci/kfaa187.33404626
Chappell, GA; Wolf, JC; Thompson, CM. (2022). Crypt and villus transcriptomic responses in mouse small intestine following oral exposure to hexavalent chromium. Toxicol Sci 186: 43–57. 10.1093/toxsci/kfab152.34935971
Chatham-Stephens, K; Caravanos, J; Ericson, B; Sunga-Amparo, J; Susilorini, B; Sharma, P; Landrigan, PJ; Fuller, R. (2013). Burden of disease from toxic waste sites in India, indonesia, and the Philippines in 2010. Environ Health Perspect 121: 791–796. 10.1289/ehp.1206127.23649493
Chen, F; Bower, J; Leonard, SS; Ding, M; Lu, Y; Rojanasakul, Y; Kung, HF; Vallyathan, V; Castranova, V; Shi, X. (2002). Protective roles of NF-kappa B for chromium(VI)-induced cytotoxicity is revealed by expression of Ikappa B kinase-beta mutant. J Biol Chem 277: 3342–3349. 10.1074/jbc.M101089200.11726646
Chen, J; Thilly, WG. (1994a). Mutational spectrum of chromium(VI) in human cells. Mutat Res 323: 21–27. 10.1016/0165-7992(94)90040-X.7508562
Chen, J; Thilly, WG. (1994b). Use of Denaturing-Gradient Gel Electrophoresis to Study Chromium-Induced Point Mutations in Human Cells. Environ Health Perspect 102: 227–229. 10.1289/ehp.94102s3227.7843103
Chen, QY; Murphy, A; Sun, H; Costa, M. (2019a). Molecular and epigenetic mechanisms of Cr(VI)-induced carcinogenesis [Review]. Toxicol Appl Pharmacol 377: 114636. 10.1016/j.taap.2019.114636.31228494
Chen, Y; Cohen, MD; Snow, ET; Costa, M. (1991). Alteration in restriction enzyme digestion patterns detects DNA--protein complexes induced by chromate. Carcinogenesis 12: 1575–1580. 10.1093/carcin/12.9.1575.1654225
Chen, ZH; Luo, NY; Ren, XH; Wang, SQ; Huang, C; Liu, YG; Liu, JJ. (2019b). [Analysis of the potential role of SET in chromium-induced malignant transformation cells based on quantitative proteomics]. Zhonghua Laodong Weisheng Zhiyebing Zazhi 37: 169–173. 10.3760/cma.j.issn.1001-9391.2019.03.002.31189235
Cheng, L; Liu, S; Dixon, K. (1998). Analysis of repair and mutagenesis of chromium-induced DNA damage in yeast, mammalian cells, and transgenic mice. Environ Health Perspect 106: 1027–1032.9703488
Cheng, L; Sonntag, DM; de Boer, J; Dixon, K. (2000). Chromium(VI)-induced mutagenesis in the lungs of big blue transgenic mice. J Environ Pathol Toxicol Oncol 19: 239–249.10983890
Chiazze, L; Ference, LD; Wolf, PH. (1980). Mortality among automobile assembly workers. I. Spray painters. J Occup Med 22: 520–526.7400865
Choi, KM; Zhu, J; Stoltz, GJ; Vernino, S; Camilleri, M; Szurszewski, JH; Gibbons, SJ; Farrugia, G. (2007). Determination of gastric emptying in nonobese diabetic mice. Am J Physiol Gastrointest Liver Physiol 293: G1039–G1045. 10.1152/ajpgi.00317.2007.17884976
Chow, WH; Malker, HSR; Hsing, AW; Mclaughlin, JK; Weiner, JA; Stone, BJ; Ericsson, JLE; Blot, WJ. (1994). Occupational risks for colon-cancer in Sweden. J Occup Environ Med 36: 647–651.
Chow, WH; McLaughlin, JK; Malker, HS; Linet, MS; Weiner, JA; Stone, BJ. (1995). Esophageal cancer and occupation in a cohort of Swedish men. Am J Ind Med 27: 749–757. 10.1002/ajim.4700270509.7611309
Christensen, MM; Ernst, E; Ellermann-Eriksen, S. (1992). Cytotoxic effects of hexavalent chromium in cultured murine macrophages. Arch Toxicol 66: 347–353.1376984
Christiansen, PM. (1968). The incidence of achlorhydria and hypochlorhydria in healthy subjects and patients with gastrointestinal diseases. Scand J Gastroenterol 3: 497–508. 10.3109/00365526809179909.5706664
Chuang, SM; Liou, GY; Yang, JL. (2000). Activation of JNK, p38 and ERK mitogen-activated protein kinases by chromium(VI) is mediated through oxidative stress but does not affect cytotoxicity. Carcinogenesis 21: 1491–1500.10910949
Chuang, SM; Yang, JL. (2001). Comparison of roles of three mitogen-activated protein kinases induced by chromium(VI) and cadmium in non-small-cell lung carcinoma cells. Mol Cell Biochem 222: 85–95.11678615
Chun, G; Bae, D; Nickens, K; O'Brien, TJ; Patierno, S. R.; Ceryak, S. (2010). Polo-like kinase 1 enhances survival and mutagenesis after genotoxic stress in normal cells through cell cycle checkpoint bypass. Carcinogenesis 31: 785–793. 10.1093/carcin/bgq014.20089605
Cid, MG; Loria, D; Vilensky, M; Miotti, JL; Matos, E. (1991). Leather tanning workers: chromosomal aberrations in peripheral lymphocytes and micronuclei in exfoliated cells in urine. Mutat Res 259: 197–201. 10.1016/0165-1218(91)90053-O.1994245
Cikrt, M; Bencko, V. (1979). Biliary excretion and distribution of 51Cr(III) and 51Cr(VI) in rats. J Hyg Epidemiol Microbiol Immunol 23: 241–246.
Clancy, HA; Sun, H; Passantino, L; Kluz, T; Muñoz, A; Zavadil, J; Costa, M. (2012). Gene expression changes in human lung cells exposed to arsenic, chromium, nickel or vanadium indicate the first steps in cancer. Metallomics 4: 784–793. 10.1039/c2mt20074k.22714537
Clementino, M; Kim, D; Zhang, Z. (2019). Constitutive Activation of NAD-Dependent Sirtuin 3 Plays an Important Role in Tumorigenesis of Chromium(VI)-Transformed Cells. Toxicol Sci 169: 224–234. 10.1093/toxsci/kfz032.30715550
Cocco, P; Ward, MH; Dosemeci, M. (1998). Occupational risk factors for cancer of the gastric cardia: Analysis of death certificates from 24 US states. J Occup Environ Med 40: 855–861.9800169
Coelho, P; García-Lestón, J; Costa, S; Costa, C; Silva, S; Dall'Armi, V; Zoffoli, R; Bonassi, S; de Lima, JP; Gaspar, JF; Pásaro, E; Laffon, B; Teixeira, JP. (2013). Genotoxic effect of exposure to metal(loid)s. A molecular epidemiology survey of populations living and working in Panasqueira mine area, Portugal. Environ Int 60: 163–170. 10.1016/j.envint.2013.08.014.24036326
Cohen, M; Costa, M. (2000). Chromium. In M Lippmann (Ed.), Environmental toxicants: Human exposures and their health effects (2nd ed., pp. 173–192). New York, NC: Wiley.
Cohen, MD; Costa, M. (1992). Chromium Compounds.
Cohen, MD; Prophete, C; Sisco, M; Chen, LC; Zelikoff, JT; Smee, JJ; Holder, AA; Crans, DC. (2006). Pulmonary immunotoxic potentials of metals are governed by select physicochemical properties: chromium agents. J Immunotoxicol 3: 69–81. 10.1080/15476910600718434.18958687
Cohen, MD; Sisco, M; Prophete, C; Yoshida, K; Chen, LC; Zelikoff, JT; Smee, J; Holder, AA; Stonehuerner, J; Crans, DC; Ghio, AJ. (2010). Effects of metal compounds with distinct physicochemical properties on iron homeostasis and antibacterial activity in the lungs: Chromium and vanadium. Inhal Toxicol 22: 169–178. 10.3109/08958370903161232.19757987
Cohen, MD; Zelikoff, JT; Chen, LC; Schlesinger, RB. (1997). Pulmonary retention and distribution of inhaled chromium: effects of particle solubility and coexposure to ozone. Inhal Toxicol 9: 843–865.
Cohen, MD; Zelikoff, JT; Chen, LC; Schlesinger, RB. (1998). Immunotoxicologic effects of inhaled chromium: role of particle solubility and co-exposure to ozone. Toxicol Appl Pharmacol 152: 30–40. 10.1006/taap.1998.8502.9772197
Cohen, RE; Neiders, ME; Bedi, GS; Comeau, R. (1993). Induction of type 2 cystatin in rat submandibular glands by systemically administered agents. Arch Oral Biol 38: 319–325.7686006
Cole, P; Rodu, B. (2005). Epidemiologic studies of chrome and cancer mortality: a series of meta-analyses. Regul Toxicol Pharmacol 43: 225–231. 10.1016/j.yrtph.2005.06.009.16099572
Collins, BJ; Stout, MD; Levine, KE; Kissling, GE; Melnick, RL; Fennell, TR; Walden, R; Abdo, K; Pritchard, JB; Fernando, RA; Burka, LT; Hooth, MJ. (2010). Exposure to hexavalent chromium resulted in significantly higher tissue chromium burden compared with trivalent chromium following similar oral doses to male F344/N rats and female B6C3F1 mice. Toxicol Sci 118: 368–379. 10.1093/toxsci/kfq263.20843897
Comess, S; Donovan, G; Gatziolis, D; Deziel, NC. (2021). Exposure to atmospheric metals using moss bioindicators and neonatal health outcomes in Portland, Oregon. Environ Pollut 284: 117343. 10.1016/j.envpol.2021.117343.34030082
Coniglio, WA; Fagliano, J; Goldoft, M; Udasin, I; Miller, S. (1990). Urinary excretion of chromium, an index of exposure.
Coogan, TP; Motz, J; Snyder, CA; Squibb, KS; Costa, M. (1991a). Differential DNA-protein crosslinking in lymphocytes and liver following chronic drinking water exposure of rats to potassium chromate. Toxicol Appl Pharmacol 109: 60–72. 10.1016/0041-008X(91)90191-G.2038750
Coogan, TP; Squibb, KS; Motz, J; Kinney, PL; Costa, M. (1991b). Distribution of chromium within cells of the blood. Toxicol Appl Pharmacol 108: 157–166. 10.1016/0041-008X(91)90279-N.2006503
Corbett, GE; Dodge, DG; O'Flaherty, E; Liang, J; Throop, L; Finley, BL; Kerger, BD. (1998). In vitro reduction kinetics of hexavalent chromium in human blood. Environ Res 78: 7–11. 10.1006/enrs.1998.3840.9630439
Corbett, GE; Finley, BL; Paustenbach, DJ; Kerger, BD. (1997). Systemic uptake of chromium in human volunteers following dermal contact with hexavalent chromium (22 mg/L). J Expo Anal Environ Epidemiol 7: 179–189.9185011
Costa, G; Merletti, F; Segnan, N. (1989). A mortality cohort study in a north Italian aircraft factory. Br J Ind Med 46: 738–743. 10.1136/oem.46.10.738.2818961
Costa, M. (1991). DNA-protein complexes induced by chromate and other carcinogens. Environ Health Perspect 92: 45–52. 10.2307/3431136.1935851
Costa, M. (1993). Molecular targets of nickel and chromium in human and experimental systems. Scand J Work Environ Health 19: 71–74.8159979
Costa, M. (1997). Toxicity and carcinogenicity of Cr(VI) in animal models and humans [Review]. Crit Rev Toxicol 27: 431–442. 10.3109/10408449709078442.9347224
Costa, M; Klein, CB. (2006). Toxicity and carcinogenicity of chromium compounds in humans [Review]. Crit Rev Toxicol 36: 155–163. 10.1080/10408440500534032.16736941
Costa, M; Salnikow, K; Sutherland, JE; Broday, L; Peng, W; Zhang, Q; Kluz, T. (2002a). The role of oxidative stress in nickel and chromate genotoxicity [Review]. Mol Cell Biochem 234–235: 265–275.
Costa, M; Salnikow, K; Sutherland, JE; Kluz, T; Peng, W; Tang, MS. (2002b). Molecular responses of mammalian cells to nickel and chromate exposure. In SH Wilson; W Suk (Eds.), Biomarkers of environmentally associated disease: Technologies, concepts, and perspectives (pp. 261–265). Boca Raton, FL: Lewis.
Costa, M; Zhitkovich, A; Toniolo, P. (1993). DNA-protein cross-links in welders: molecular implications. Cancer Res 53: 460–463.8425177
Costa, M; Zhitkovich, A; Toniolo, P; Taioli, E; Popov, T; Lukanova, A. (1996). Monitoring human lymphocytic DNA-protein cross-links as biomarkers of biologically active doses of chromate. Environ Health Perspect 104 Suppl 5: 917–919.
Costantini, AS; Paci, E; Miligi, L; Buiatti, E; Martelli, C; Lenzi, S. (1989). Cancer mortality among workers in the Tuscan tanning industry. Br J Ind Med 46: 384–388. 10.1136/oem.46.6.384.2818971
COT (Committee on Toxicity). (2015). Committees on toxicity, mutagenicity, carcinogenicity of chemicals in food, consumer products and the environment. https://cot.food.gov.uk/sites/default/files/annualreport2015.pdf.
Crump, C; Crump, K; Hack, E; Luippold, R; Mundt, K; Liebig, E; Panko, J; Paustenbach, D; Proctor, D. (2003). Dose-response and risk assessment of airborne hexavalent chromium and lung cancer mortality. Risk Anal 23: 1147–1163. 10.1111/j.0272-4332.2003.00388.x.14641890
Cullen, JM; Ward, JM; Thompson, CM. (2015). Reevaluation and Classification of Duodenal Lesions in B6C3F1 Mice and F344 Rats from 4 Studies of Hexavalent Chromium in Drinking Water. Toxicol Pathol 44: 279–289. 10.1177/0192623315611501.26538584
Cupo, DY; Wetterhahn, KE. (1985). Binding of chromium to chromatin and DNA from liver and kidney of rats treated with sodium dichromate and chromium(III) chloride in vivo. Cancer Res 45: 1146–1151.2578874
Curtis, A; Morton, J; Balafa, C; Macneil, S; Gawkrodger, DJ; Warren, ND; Evans, GS. (2007). The effects of nickel and chromium on human keratinocytes: differences in viability, cell associated metal and IL-1alpha release. Toxicol In Vitro 21: 809–819. 10.1016/j.tiv.2007.01.026.17368827
D'Agostini, F; Izzotti, A; Bennicelli, C; Camoirano, A; Tampa, E; De Flora, S. (2002). Induction of apoptosis in the lung but not in the liver of rats receiving intra-tracheal instillations of chromium(VI). Carcinogenesis 23: 587–593. 10.1093/carcin/23.4.587.11960910
Dab, W; Rossignol, M; Luce, D; Benichou, J; Marconi, A; Clement, P; Aubier, M; Zmirou-Navier, D; Abenhaim, L. (2011). Cancer mortality study among French cement production workers. Int Arch Occup Environ Health 84: 167–173. 10.1007/s00420-010-0530-6.20358379
Dagli, MLZ; Pandiri, A; Wolf, J; Groeters, S; Haschek-Hock, WM. (2019). Global perspective on careers in environmental toxicologic pathology: The 2019 Society of Toxicologic Pathology Annual Symposium Lunchtime Career Development Session. Toxicol Pathol 47: 1088–1095. 10.1177/0192623319877.31554482
Dai, H; Liu, J; Malkas, LH; Catalano, J; Alagharu, S; Hickey, RJ. (2009). Chromium reduces the in vitro activity and fidelity of DNA replication mediated by the human cell DNA synthesome. Toxicol Appl Pharmacol 236: 154–165. 10.1016/j.taap.2008.12.028.19371627
Dai, J; Ji, Y; Wang, W; Kim, D; Fai, LY; Wang, L; Luo, J; Zhang, Z. (2017a). Loss of fructose-1,6-bisphosphatase induces glycolysis and promotes apoptosis resistance of cancer stem-like cells: An important role in hexavalent chromium-induced carcinogenesis. Toxicol Appl Pharmacol 331: 164–173. 10.1016/j.taap.2017.06.014.28624442
Dai, L; Xu, W; Li, H; Frank, JA; He, C; Zhang, Z; Chen, G. (2017b). Effects of hexavalent chromium on mouse splenic T lymphocytes. Toxicol In Vitro 45: 166–171. 10.1016/j.tiv.2017.09.006.28899767
Dalager, NA; Mason, TJ; Fraumeni, JF; Hoover, R; Payne, WW. (1980). Cancer mortality among workers exposed to zinc chromate paints. J Occup Med 22: 25–29.7354410
Dana Devi, K; Rozati, R; Saleha Banu, B; Jamil, K; Grover, P. (2001). In vivo genotoxic effect of potassium dichromate in mice leukocytes using comet assay. Food Chem Toxicol 39: 859–865.11434993
Danadevi, K; Rozati, R; Banu, BS; Grover, P. (2004). Genotoxic evaluation of welders occupationally exposed to chromium and nickel using the Comet and micronucleus assays. Mutagenesis 19: 35–41. 10.1093/mutage/geh001.14681311
Danielsen, TE; Langård, S; Andersen, A. (1996). Incidence of cancer among Norwegian boiler welders. Occup Environ Med 53: 231–234. 10.1136/oem.53.4.231.8664959
Danielsen, TE; Langard, S; Andersen, A; Knudsen, O. (1993). INCIDENCE OF CANCER AMONG WELDERS OF MILD-STEEL AND OTHER SHIPYARD WORKERS. Br J Ind Med 50: 1097–1103. 10.1136/oem.50.12.1097.8280640
Das, J; Kang, MH; Kim, E; Kwon, DN; Choi, YJ; Kim, JH. (2015). Hexavalent chromium induces apoptosis in male somatic and spermatogonial stem cells via redox imbalance. Sci Rep 5: 13921. 10.1038/srep13921.26355036
Davidson, T; Kluz, T; Burns, F; Rossman, T; Zhang, Q; Uddin, A; Nadas, A; Costa, M. (2004). Exposure to chromium (VI) in the drinking water increases susceptibility to UV-induced skin tumors in hairless mice. Toxicol Appl Pharmacol 196: 431–437. 10.1016/j.taap.2004.01.006.15094314
Davies, JM; Easton, DF; Bidstrup, PL. (1991). Mortality from respiratory cancer and other causes in United Kingdom chromate production workers. Br J Ind Med 48: 299–313.2039742
De Flora, S. (1979). Metabolic activation and deactivation of mutagens and carcinogens. Ital J Biochem 28: 81–103.399955
De Flora, S. (1981). Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2: 283–298. 10.1093/carcin/2.4.283.7023727
De Flora, S; Badolati, GS; Serra, D; Picciotto, A; Magnolia, MR; Savarino, V. (1987a). Circadian reduction of chromium in the gastric environment. Mutat Res Lett 192: 169–174. 10.1016/0165-7992(87)90051-0.
De Flora, S; Camoirano, A; Bagnasco, M; Bennicelli, C; Corbett, GE; Kerger, BD. (1997). Estimates of the chromium(VI) reducing capacity in human body compartments as a mechanism for attenuating its potential toxicity and carcinogenicity. Carcinogenesis 18: 531–537.9067553
De Flora, S; Camoirano, A; Micale, RT; La Maestra, S; Savarino, V; Zentilin, P; Marabotto, E; Suh, M; Proctor, DM. (2016). Reduction of hexavalent chromium by fasted and fed human gastric fluid. I. Chemical reduction and mitigation of mutagenicity. Toxicol Appl Pharmacol 306: 113–119. 10.1016/j.taap.2016.07.004.27404458
De Flora, S; D'Agostini, F; Balansky, R; Micale, R; Baluce, B; Izzotti, A. (2008). Lack of genotoxic effects in hematopoietic and gastrointestinal cells of mice receiving chromium(VI) with the drinking water [Review]. Mutat Res 659: 60–67. 10.1016/j.mrrev.2007.11.005.18155955
De Flora, S; Iltcheva, M; Balansky, RM. (2006). Oral chromium(VI) does not affect the frequency of micronuclei in hematopoietic cells of adult mice and of transplacentally exposed fetuses. Mutat Res 610: 38–47. 10.1016/j.mrgentox.2006.06.011.16872865
De Flora, S; Morelli, A; Basso, C; Romano, M; Serra, D; De Flora, A. (1985). Prominent role of DT-diaphorase as a cellular mechanism reducing chromium(VI) and reverting its mutagenicity. Cancer Res 45: 3188–3196.4005852
De Flora, S; Petruzzelli, S; Camoirano, A; Bennicelli, C; Romano, M; Rindi, M; Ghelarducci, L; Giuntini, C. (1987b). Pulmonary metabolism of mutagens and its relationship with lung cancer and smoking habits. Cancer Res 47: 4740–4745.3621172
De Flora, S; Zanacchi, P; Camoirano, A; Bennicelli, C; Badolati, GS. (1984). Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test [Review]. Mutat Res 133: 161–198. 10.1016/0165-1110(84)90016-2.6374443
De Mattia, G; Bravi, MC; Laurenti, O; De Luca, O; Palmeri, A; Sabatucci, A; Mendico, G; Ghiselli, A. (2004). Impairment of cell and plasma redox state in subjects professionally exposed to chromium. Am J Ind Med 46: 120–125. 10.1002/ajim.20044.15273963
De Smet, B; Depoortere, I; Moechars, D; Swennen, Q; Moreaux, B; Cryns, K; Tack, J; Buyse, J; Coulie, B; Peeters, TL. (2006). Energy homeostasis and gastric emptying in ghrelin knockout mice. J Pharmacol Exp Ther 316: 431–439. 10.1124/jpet.105.091504.16203827
Debetto, P; Arslan, P; Antolini, M; Luciani, S. (1988). Uptake of chromate by rat thymocytes and role of glutathione in its cytoplasmic reduction. Xenobiotica 18: 657–664. 10.3109/00498258809041704.3420944
Deloughery, Z; Luczak, MW; Ortega-Atienza, S; Zhitkovich, A. (2015). DNA double-strand breaks by Cr(VI) are targeted to euchromatin and cause ATR-dependent phosphorylation of histone H2AX and its ubiquitination. Toxicol Sci 143: 54–63. 10.1093/toxsci/kfu207.25288669
Delzell, E; Brown, DA; Matthews, R. (2003). Mortality among hourly motor vehicle manufacturing workers. J Occup Environ Med 45: 813–830. 10.1097/01.jom.0000079092.95532.49.12915783
Delzell, E; Macaluso, M; Honda, Y; Austin, H. (1993). Mortality patterns among men in the motor-vehicle manufacturing-industry. Am J Ind Med 24: 471–484. 10.1002/ajim.4700240411.8250065
Den Braver-Sewradj, SP; van Benthem, J; Staal, YCM; Ezendam, J; Piersma, AH; Hessel, EVS. (2021). Occupational exposure to hexavalent chromium. Part II. Hazard assessment of carcinogenic effects. Regul Toxicol Pharmacol 126: 105045. 10.1016/j.yrtph.2021.105045.34506880
Deng, C; Lee, HH; Xian, H; Yao, M; Huang, J; Ou, B. (1988). Chromosomal aberrations and sister chromatid exchanges of peripheral blood lymphocytes in Chinese electroplating workers: Effect of nickel and chromium. J Trace Elem Exp Med 1: 57–62.
Deng, Y; Wang, M; Tian, T; Lin, S; Xu, P; Zhou, L; Dai, C; Hao, Q; Wu, Y; Zhai, Z; Zhu, Y; Zhuang, G; Dai, Z. (2019). The Effect of Hexavalent Chromium on the Incidence and Mortality of Human Cancers: A Meta-Analysis Based on Published Epidemiological Cohort Studies. 9: 24. 10.3389/fonc.2019.00024.
Denniston, ML; Uyeki, EM. (1987). Distribution and HPLC study of chromium-51 binding sites in Chinese hamster ovary cells. J Toxicol Environ Health 21: 375–386. 10.1080/15287398709531026.3586066
Deschamps, F; Moulin, JJ; Wild, P; Labriffe, H; Haguenoer, JM. (1995). Mortality study among workers producing chromate pigments in France. Int Arch Occup Environ Health 67: 147–152. 10.1007/BF00626345.7591171
Desmarais, TL; Costa, M. (2019). Mechanisms of Chromium-Induced Toxicity. Curr Opin Toxicol 14: 1–7. 10.1016/j.cotox.2019.05.003.31511838
Devoy, J; Cosnier, F; Bonfanti, E; Antoine, G; Nunge, H; Lambert-Xolin, AM; Décret, MJ; Douteau, L; Lorcin, M; Sébillaud, S; Grossmann, S; Michaux, S; Müller, S; Viton, S; Seidel, C; Gaté, L. (2019). Intra-erythrocyte chromium as an indicator of exposure to hexavalent chromium: An in vivo evaluation in intravenous administered rat. Toxicol Lett 314: 133–141. 10.1016/j.toxlet.2019.07.020.31325633
Devoy, J; Géhin, A; Müller, S; Melczer, M; Remy, A; Antoine, G; Sponne, I. (2016). Evaluation of chromium in red blood cells as an indicator of exposure to hexavalent chromium: An in vitro study. Toxicol Lett 255: 63–70. 10.1016/j.toxlet.2016.05.008.27178267
Dillon, CT; Lay, PA; Kennedy, BJ; Stampfl, AP; Cai, Z; Ilinski, P; Rodrigues, W; Legnini, DG; Lai, B; Maser, J. (2002). Hard X-ray microprobe studies of chromium(VI)-treated V79 Chinese hamster lung cells: intracellular mapping of the biotransformation products of a chromium carcinogen. J Biol Inorg Chem 7: 640–645. 10.1007/s00775-002-0343-5.12072970
Ding, SZ; Yang, YX; Li, XL; Michelli-Rivera, A; Han, SY; Wang, L; Pratheeshkumar, P; Wang, X; Lu, J; Yin, YQ; Budhraja, A; Hitron, AJ. (2013). Epithelial-mesenchymal transition during oncogenic transformation induced by hexavalent chromium involves reactive oxygen species-dependent mechanism in lung epithelial cells. Toxicol Appl Pharmacol 269: 61–71. 10.1016/j.taap.2013.03.006.23518002
Dipaolo, JA; Casto, BC. (1979). Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39: 1008–1013.427740
Divine, BJ; Barron, V. (1986). Texaco mortality study: II. Patterns of mortality among white males by specific job groups. Am J Ind Med 10: 371–381. 10.1002/ajim.4700100405.3788982
Dlugosz, A; Rembacz, KP; Pruss, A; Durlak, M; Lembas-Bogaczyk, J. (2012). Influence of chromium on the natural antioxidant barrier. Pol J Environ Stud 21: 331–335.
Döker, S; Mounicou, S; Doğan, M; Lobinski, R. (2010). Probing the metal-homeostatis effects of the administration of chromium(vi) to mice by ICP MS and size-exclusion chromatography-ICP MS. Metallomics 2: 549–555. 10.1039/c004508j.21072339
Donaldson, RM, Jr; Barreras, RF. (1966). Intestinal absorption of trace quantities of chromium. J Lab Clin Med 68: 484–493.5922758
Dou, Y; Yin, Y; Li, Z; Du, J; Jiang, Y; Jiang, T; Guo, W; Qin, R; Li, M; Lv, H; Lu, Q; Qiu, Y; Lin, Y; Jin, G; Lu, C; Ma, H; Hu, Z. (2022). Maternal exposure to metal mixtures during early pregnancy and fetal growth in the Jiangsu Birth Cohort, China. Environ Res 215: 114305. 10.1016/j.envres.2022.114305.36096164
Downs, BW; Sauder, HM. (2023). Septal perforation. In StatPearls. Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK537208/.
Dressman, JB; Berardi, RR; Dermentzoglou, LC; Russell, TL; Schmaltz, SP; Barnett, JL; Jarvenpaa, KM. (1990). Upper gastrointestinal (GI) pH in young, healthy men and women. Pharm Res 7: 756–761.2395805
Dubrovskaya, VA; Wetterhahn, KE. (1998). Effects of Cr(VI) on the expression of the oxidative stress genes in human lung cells. Carcinogenesis 19: 1401–1407.9744536
Dubrow, R; Gute, DM. (1988). Cause-specific mortality among male textile workers in Rhode Island. Am J Ind Med 13: 439–454. 10.1002/ajim.4700130404.3364422
Dubrow, R; Wegman, DH. (1984). Cancer and occupation in Massachusetts: A death certificate study. Am J Ind Med 6: 207–230. 10.1002/ajim.4700060305.6475966
Dunkel, VC; Pienta, RJ; Sivak, A; Traul, KA. (1981). Comparative neoplastic transformation responses of Balb/3T3 cells, Syrian hamster embryo cells, and Rauscher murine leukemia virus-infected Fischer 344 rat embryo cells to chemical compounds. J Natl Cancer Inst 67: 1303–1312.6947113
Dunkel, VC; Zeiger, E; Brusick, D; McCoy, E; McGregor, D; Mortelmans, K; Rosenkranz, HS; Simmon, VF. (1984). Reproducibility of microbial mutagenicity assays: I. Tests with Salmonella typhimurium and Escherichia coli using a standardized protocol. Environ Mutagen 6: 1–251. 10.1002/em.2860060704.
Eastmond, DA; MacGregor, JT; Slesinski, RS. (2008). Trivalent chromium: Assessing the genotoxic risk of an essential trace element and widely used human and animal nutritional supplement. Crit Rev Toxicol 38: 173–190. 10.1080/10408440701845401.18324515
EC (European Commission). (2015). Opinion on Chromium VI in toys. Luxembourg. 10.2772/41993.
Edel, J; Sabbioni, E. (1985). Pathways of Cr (III) and Cr (VI) in the rat after intratracheal administration. Hum Exp Toxicol 4: 409–416.
Edling, C; Kling, H; Flodin, U; Axelson, O. (1986). Cancer mortality among leather tanners. Br J Ind Med 43: 495–496. 10.1136/oem.43.7.494.
EFSA CONTAM Panel (EFSA Panel on Contaminants in the Food Chain). (2014). Scientific Opinion on the risks to public health related to the presence of chromium in food and drinking water. EFSA J 12: 3595. 10.2903/j.efsa.2014.3595.
Egger, M; Smith, GD; Schneider, M; Minder, C. (1997). Bias in meta-analysis detected by a simple, graphical test. Br Med J 315: 629–634. 10.1136/bmj.315.7109.629.9310563
El-Demerdash, FM; Jebur, AB; Nasr, HM; Hamid, HM. (2019). Modulatory effect of Turnera diffusa against testicular toxicity induced by fenitrothion and/or hexavalent chromium in rats. Environ Toxicol 34: 330–339. 10.1002/tox.22688.30578656
El-Yamani, N; Zúñiga, L; Stoyanova, E; Creus, A; Marcos, R. (2011). Chromium-induced genotoxicity and interference in human lymphoblastoid cell (TK6) repair processes. J Toxicol Environ Health A 74: 1030–1039. 10.1080/15287394.2011.582282.21707427
El Safty, AMK; Samir, AM; Mekkawy, MK; Fouad, MM. (2018). Genotoxic effects due to exposure to chromium and nickel among electroplating workers. Int J Toxicol 37: 234–240. 10.1177/1091581818764084.29554825
Elhosary, N; Maklad, A; Soliman, E; El-Ashmawy, N; Oreby, M. (2014). Evaluation of oxidative stress and DNA damage in cement and tannery workers in Egypt. Inhal Toxicol 26: 289–298. 10.3109/08958378.2014.885100.24617565
Elia, MC; Storer, RD; Mckelvey, TW; Kraynak, AR; Barnum, JE; Harmon, LS; Deluca, JG; Nichols, WW. (1994). Rapid DNA degradation in primary rat hepatocytes treated with diverse cytotoxic chemicals: Analysis by pulsed field gel electrophoresis and implications for alkaline elution assays. Environ Mol Mutagen 24: 181–191.7957122
Elias, Z; Poirot, O; Baruthio, F; Daniere, MC. (1991). Role of solubilized chromium in the induction of morphological transformation of Syrian hamster embryo (SHE) cells by particulate chromium(VI) compounds. Carcinogenesis 12: 1811–1816. 10.1093/carcin/12.10.1811.1934262
Ellinger-Ziegelbauer, H; Stuart, B; Wahle, B; Bomann, W; Ahr, HJ. (2005). Comparison of the expression profiles induced by genotoxic and nongenotoxic carcinogens in rat liver. Mutat Res 575: 61–84. 10.1016/j.mrfmmm.2005.02.004.15890375
EMEA (European Medicines Agency). (2010). Reflection paper on non-clinical evaluation of drug-induced liver injury (DILI). (EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2010/07/WC500094591.pdf.
Enck, P; Wienbeck, M. (1989). Repeated noninvasive measurement of gastrointestinal transit in rats. Physiol Behav 46: 633–637. 10.1016/0031-9384(89)90343-0.2602487
Engel, LS; Vaughan, TL; Gammon, MD; Chow, WH; Risch, HA; Dubrow, R; Mayne, ST; Rotterdam, H; Schoenberg, JB; Stanford, JL; West, AB; Blot, WJ; Fraumeni, JF. (2002). Occupation and risk of esophageal and gastric cardia adenocarcinoma. Am J Ind Med 42: 11–22. 10.1002/ajim.10077.12111686
Ewis, AA; Kondo, K; Dang, F; Nakahori, Y; Shinohara, Y; Ishikawa, M; Baba, Y. (2006). Surfactant protein B gene variations and susceptibility to lung cancer in chromate workers. Am J Ind Med 49: 367–373. 10.1002/ajim.20283.16570259
Fagliano, JA; Savrin, J; Udasin, I; Gochfeld, M. (1997). Community exposure and medical screening near chromium waste sites in New Jersey. Regul Toxicol Pharmacol 26: S13–S22. 10.1006/rtph.1997.1134.9380833
Faux, SP; Gao, M; Aw, TC; Braithwaite, RA; Levy, LS. (1994). Molecular epidemiological studies in workers exposed to chromium-containing compounds. Clin Chem 40: 1454–1456.
FDA. Requirements for specific standardized beverages: Bottled water, 21 CFR 165.110 (2013). https://www.govinfo.gov/app/details/CFR-2013-title21-vol2/CFR-2013-title21-vol2-sec165–110/
Fébel, H; Szegedi, B; Huszár, S. (2001). Absorption of inorganic, trivalent and hexavalent chromium following oral and intrajejunal doses in rats. Acta Vet Hung 49: 203–209.11402649
Federal Register. (2010). Federal Register: March 29 2010 National Primary Drinking Water Regulations Announcement of the Results of EPA’s Review of Existing Drinking Water Standards and Request for Public Comment and/or Information on Related Issues Notice. (815Z10001). http://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P1007TNX.txt.
Feldman, M; Barnett, C. (1991). Fasting gastric pH and its relationship to true hypochlorhydria in humans. Dig Dis Sci 36: 866–869. 10.1007/BF01297133.2070698
Fernandes, MA; Mota, IM; Silva, MT; Oliveira, CR; Geraldes, CF; Alpoim, MC. (1999). Human erythrocytes are protected against chromate-induced peroxidation. Ecotoxicol Environ Saf 43: 38–46. 10.1006/eesa.1998.1755.10330319
Figgitt, M; Newson, R; Leslie, IJ; Fisher, J; Ingham, E; Case, CP. (2010). The genotoxicity of physiological concentrations of chromium (Cr(III) and Cr(VI)) and cobalt (Co(II)): an in vitro study. Mutat Res 688: 53–61. 10.1016/j.mrfmmm.2010.03.008.20227425
Finkelstein, MM; Verma, DK. (2005). Mortality among Ontario members of the International Union of Bricklayers and Allied Craftworkers. Am J Ind Med 47: 4–9. 10.1002/ajim.20116.15597359
Finley, BL; Kerger, BD; Katona, MW; Gargas, ML; Corbett, GC; Paustenbach, DJ. (1997). Human ingestion of chromium (VI) in drinking water: pharmacokinetics following repeated exposure. Toxicol Appl Pharmacol 142: 151–159. 10.1006/taap.1996.7993.9007044
Finley, BL; Scott, PK; Norton, RL; Gargas, ML; Paustenbach, DJ. (1996). Urinary chromium concentrations in humans following ingestion of safe doses of hexavalent and trivalent chromium: implications for biomonitoring. J Toxicol Environ Health 48: 479–499. 10.1080/009841096161195.8751836
Flores, A; Pérez, JM. (1999). Cytotoxicity, apoptosis, and in vitro DNA damage induced by potassium chromate. Toxicol Appl Pharmacol 161: 75–81. 10.1006/taap.1999.8779.10558925
Fornace, AJ. (1982). Detection of DNA single-strand breaks produced during the repair of damage by DNA-protein cross-linking agents. Cancer Res 42: 145–149.7198506
Fornace, AJ, Jr; Seres, DS; Lechner, JF; Harris, CC. (1981). DNA-protein cross-linking by chromium salts. Chem Biol Interact 36: 345–354. 10.1016/0009-2797(81)90077-6.7285240
Franchini, I; Magnani, F; Mutti, A. (1983). Mortality experience among chromeplating workers. Initial findings. Scand J Work Environ Health 9: 247–252. 10.5271/sjweh.2413.6612265
Freire, C; Amaya, E; Gil, F; Murcia, M; Llop, S; Casas, M; Vrijheid, M; Lertxundi, A; Irizar, A; Fernández-Tardón, G; Castro-Delgado, RV; Olea, N; Fernández, MF. (2019). Placental metal concentrations and birth outcomes: The Environment and Childhood (INMA) project. Int J Hyg Environ Health 222: 468–478. 10.1016/j.ijheh.2018.12.014.30638867
Frentzel-Beyme, R. (1983). Lung cancer mortality of workers employed in chromate pigment factories: a multicentric European epidemiological study. J Cancer Res Clin Oncol 105: 183–188. 10.1007/bf00406930.6826639
Friis-Hansen, L; Sundler, F; Li, Y; Gillespie, PJ; Saunders, TL; Greenson, JK; Owyang, C; Rehfeld, JF; Samuelson, LC. (1998). Impaired gastric acid secretion in gastrin-deficient mice. Am J Physiol 274: G561–G568.9530158
FSC (Food Safety Commission of Japan). (2019). Hexavalent chromium (Contaminants). Food Saf 7: 56–57. 10.14252/foodsafetyfscj.D-1900002.
Fukunaga, M; Kurachi, Y; Mizuguchi, Y. (1982). Action of some metal ions on yeast chromosomes. Chem Pharm Bull (Tokyo) 30: 3017–3019. 10.1248/cpb.30.3017.6754115
Galarneau, JM; Beach, J; Cherry, N. (2022). Pregnancy Outcome in Women Exposed to Metal Fume in Welding: A Canadian Cohort Study. Ann Work Expo Health 66: 1099–1110. 10.1093/annweh/wxac024.35488367
Galvin, JB; Oberg, SG. (1984). Toxicity of hexavalent chromium to the alveolar macrophage in vivo and in vitro. Environ Res 33: 7–16. 10.1016/0013-9351(84)90003-3.6692816
Gambelunghe, A; Piccinini, R; Abbritti, G; Ambrogi, M; Ugolini, B; Marchetti, C; Migliorati, G; Balducci, C; Muzi, G. (2006). Chromium VI-induced apoptosis in a human bronchial epithelial cell line (BEAS-2B) and a lymphoblastic leukemia cell line (MOLT-4). J Occup Environ Med 48: 319–325. 10.1097/01.jom.0000197859.46894.7d.16531837
Gambelunghe, A; Piccinini, R; Ambrogi, M; Villarini, M; Moretti, M; Marchetti, C; Abbritti, G; Muzi, G. (2003). Primary DNA damage in chrome-plating workers. Toxicology 188: 187–195.12767690
Gammelgaard, B; Jensen, K; Steffansen, B. (1999). In vitro metabolism and permeation studies in rat jejunum: Organic chromium compared to inorganic chromium. J Trace Elem Med Biol 13: 82–88.10445223
Ganapathy, S; Li, P; Lafontant, J; Xiong, R; Yu, T; Zhang, G; Chen, C. (2017). Chromium IV exposure, via src/Ras signaling, promotes cell transformation. Mol Carcinog 56: 1808–1815. 10.1002/mc.22639.28218450
Gao, M; Binks, SP; Chipman, JK; Levy, LS. (1993a). Hexavalent chromium produces DNA strand breakage but not unscheduled DNA synthesis at sub-cytotoxic concentrations in hepatocytes. Toxicology 77: 171–180. 10.1016/0300-483X(93)90147-K.8442012
Gao, M; Binks, SP; Chipman, JK; Levy, LS; Braithwaite, RA; Brown, SS. (1992). Induction of DNA strand breaks in peripheral lymphocytes by soluble chromium compounds. Hum Exp Toxicol 11: 77–82. 10.1177/096032719201100203.1349223
Gao, M; Levy, LS; Braithwaite, RA; Brown, SS. (1993b). Monitoring of total chromium in rat fluids and lymphocytes following intratracheal administration of soluble trivalent or hexavalent chromium compounds. Hum Exp Toxicol 12: 377–382.7902114
Gao, M; Levy, LS; Faux, SP; Aw, TC; Braithwaite, RA; Brown, SS. (1994). Use of molecular epidemiological techniques in a pilot study on workers exposed to chromium. Occup Environ Med 51: 663–668. 10.1136/oem.51.10.663.8000490
Garabrant, D; Held, J; Langholz, B; Bernstein, L. (1988). Mortality of aircraft manufacturing workers in southern California. Am J Ind Med 13: 683–693. 10.1002/ajim.4700130607.3389363
Garabrant, DH; Wegman, DH. (1984). Cancer mortality among shoe and leather workers in Massachusetts. Am J Ind Med 5: 303–314.6720693
Garcia, JD; Jennette, KW. (1981). Electron-transport cytochrome P-450 system is involved in the microsomal metabolism of the carcinogen chromate. J Inorg Biochem 14: 281–295. 10.1016/S0162-0134(00)80286-X.6792322
Gargas, ML; Norton, RL; Harris, MA; Paustenbach, DJ; Finley, BL. (1994). Urinary excertion of chromium following ingestion of chromite-ore processing residues in humans: implications for biomonitoring. Risk Anal 14: 1019–1024.7846309
Garrison, JC; Bisel, TU; Peterson, P; Uyeki, EM. (1990). Changes in hepatocyte ploidy in response to chromium, analyzed by computer-assisted microscopy. Fundam Appl Toxicol 14: 346–355. 10.1016/0272-0590(90)90214-5.2318359
Gatto, NM; Kelsh, MA; Mai, DH; Suh, M; Proctor, DM. (2010). Occupational exposure to hexavalent chromium and cancers of the gastrointestinal tract: a meta-analysis. Cancer Detect Prev 34: 388–399. 10.1016/j.canep.2010.03.013.
Gavin, IM; Gillis, B; Arbieva, Z; Prabhakar, BS. (2007). Identification of human cell responses to hexavalent chromium. Environ Mol Mutagen 48: 650–657. 10.1002/em.20331.17685462
Ge, H; Li, Z; Jiang, L; Li, Q; Geng, C; Yao, X; Shi, X; Liu, Y; Cao, J. (2019). Cr (VI) induces crosstalk between apoptosis and autophagy through endoplasmic reticulum stress in A549 cells. Chem Biol Interact 298: 35–42. 10.1016/j.cbi.2018.10.024.30416085
Gentile, JM; Hyde, K; Schubert, J. (1981). Chromium genotoxicity as influenced by complexation and rate effects. Toxicol Lett 7: 439–448. 10.1016/0378-4274(81)90090-4.6787741
Geoffroy-Siraudin, C; Perrard, MH; Chaspoul, F; Lanteaume, A; Gallice, P; Durand, P; Guichaoua, MR. (2010). Validation of a rat seminiferous tubule culture model as a suitable system for studying toxicant impact on meiosis effect of hexavalent chromium. Toxicol Sci 116: 286–296. 10.1093/toxsci/kfq099.20360146
Gibb, H; Wang, J; OĽeary, K; Chen, C; Bateson, TF; Kopylev, L. (2020). The effect of age on the relative risk of lung cancer mortality in a cohort of chromium production workers. Am J Ind Med 63: 774–778. 10.1002/ajim.23152.32687217
Gibb, HJ; Lees, PS; Pinsky, PF; Rooney, BC. (2000a). Clinical findings of irritation among chromium chemical production workers. Am J Ind Med 38: 127–131.10893505
Gibb, HJ; Lees, PS; Pinsky, PF; Rooney, BC. (2000b). Lung cancer among workers in chromium chemical production. Am J Ind Med 38: 115–126.10893504
Gibb, HJ; Lees, PS; Wang, J; Grace OĽeary, K. (2015). Extended followup of a cohort of chromium production workers. Am J Ind Med 58: 905–913. 10.1002/ajim.22479.26041683
Gibel, W; Nischan, P; Staneczek, W. (1985). OCCUPATIONAL-CANCER OF NASAL CAVITY AND PARA-NASAL SINUSES IN WOODWORKERS. Arch Geschwulstforsch 55: 279–284.4037999
Girardi, P; Bressan, V; Mabilia, T; Merler, E. (2015). [Confirmation of an excess of cancer mortality in a cohort of workers of a chromium thin-layer plating]. Epidemiol Prev 39: 183–187.26668918
Glaser, U; Hochrainer, D; Klöeppel, H; Kuhnen, H. (1985). Low level chromium (VI) inhalation effects on alveolar macrophages and immune functions in Wistar rats. Arch Toxicol 57: 250–256. 10.1007/BF00324787.3879166
Glaser, U; Hochrainer, D; Kloeppel, H; Oldiges, H. (1986). Carcinogenicity of sodium dichromate and chromium (VI/III)oxide aerosols inhaled by male Wistar rats. Toxicology 42: 219–232. 10.1016/0300-483X(86)90011-9.3798470
Glaser, U; Hochrainer, D; Steinhoff, D. (1990). Investigation of irritating properties of inhaled Cr(VI) with possible influence on its carcinogenic action. In NH Seemayer; W Hadnagy (Eds.), Environmental hygiene II (pp. 239–245). Berlin, Germany: Springer-Verlag.
Glaviano, A; Nayak, V; Cabuy, E; Baird, DM; Yin, Z; Newson, R; Ladon, D; Rubio, MA; Slijepcevic, P; Lyng, F; Mothersill, C; Case, CP. (2006). Effects of hTERT on metal ion-induced genomic instability. Oncogene 25: 3424–3435. 10.1038/sj.onc.1209399.16449970
Goldoni, M; Caglieri, A; Corradi, M; Poli, D; Rusca, M; Carbognani, P; Mutti, A. (2008). Chromium in exhaled breath condensate and pulmonary tissue of non-small cell lung cancer patients. Int Arch Occup Environ Health 81: 487–493. 10.1007/s00420-007-0242-8.17724608
Goldoni, M; Caglieri, A; De Palma, G; Acampa, O; Gergelova, P; Corradi, M; Apostoli, P; Mutti, A. (2010). Chromium in exhaled breath condensate (EBC), erythrocytes, plasma and urine in the biomonitoring of chrome-plating workers exposed to soluble Cr(VI). J Environ Monit 12: 442–447. 10.1039/b914673c.20145884
Goldoni, M; Caglieri, A; Poli, D; Vettori, MV; Corradi, M; Apostoli, P; Mutti, A. (2006). Determination of hexavalent chromium in exhaled breath condensate and environmental air among chrome plating workers. Anal Chim Acta 562: 229–235. 10.1016/j.aca.2006.01.065.17047732
Golka, K; Roemer, HC; Weistenhöfer, W; Blaszkewicz, M; Hammad, S; Reckwitz, T; Loehlein, D; Hartel, M; Hengstler, JG; Geller, F. (2012). N-Acetyltransferase 2 and glutathione s-transferase M1 in colon and rectal cancer cases from an industrialized area. J Toxicol Environ Health A 75: 572–581. 10.1080/15287394.2012.675310.22686318
Gomes, ER. (1972). Incidence of chromium-induced lesions among electroplating workers in Brazil. Ind Med Surg 41: 21–25.
González, CA; Sanz, M; Marcos, G; Pita, S; Brullet, E; Vida, F; Agudo, A; Hsieh, CC. (1991). Occupation and gastric cancer in Spain. Scand J Work Environ Health 17: 240–247. 10.5271/sjweh.1707.1925435
Goulart, M; Batoréu, MC; Rodrigues, AS; Laires, A; Rueff, J. (2005). Lipoperoxidation products and thiol antioxidants in chromium exposed workers. Mutagenesis 20: 311–315. 10.1093/mutage/gei043.15985443
Gray, SJ; Sterling, K. (1950). The tagging of red cells and plasma proteins with radioactive chromium. J Clin Invest 29: 1604–1613. 10.1172/JCI102403.14794790
Greene, MH; Hoover, RN; Eck, RL; Fraumeni JF, J. R. (1979). Cancer mortality among printing plant workers. Environ Res 20: 66–73. 10.1016/0013-9351(79)90085–9.499172
Grimm, M; Koziolek, M; Kühn, JP; Weitschies, W. (2018). Interindividual and intraindividual variability of fasted state gastric fluid volume and gastric emptying of water. 10.1016/j.ejpb.2018.03.002.
Grlickova-Duzevik, E; Wise, SS; Munroe, RC; Thompson, WD; Wise, JP. (2006). XRCC1 protects cells from chromate-induced chromosome damage, but does not affect cytotoxicity. Mutat Res Genet Toxicol Environ Mutagen 610: 31–37. 10.1016/j.mrgentox.2006.06.010.
Gromadzińska, J; Wasowicz, W; Sklodowska, M; Bulikowski, W; Rydzyński, K. (1996). The influence of atmospheric chromium on selenium content and glutathione peroxidase activity in blood of tannery workers. Environ Health Perspect 104: 1312–1316. 10.1289/ehp.104-1469531.9118872
Gruber, JE; Jennette, KW. (1978). Metabolism of the carcinogen chromate by rat liver microsomes. Biochem Biophys Res Commun 82: 700–706. 10.1016/0006-291X(78)90931-2.27196
Gu, Y; Ohgami, N; Al Hossain, MMA; Tazaki, A; Tsuchiyama, T; He, T; Aoki, M; Ahsan, N; Akhand, AA; Kato, M. (2022). Decreased hearing levels at frequencies for understanding speech in tannery workers exposed to a high level of trivalent chromium in Bangladesh. Chemosphere 306: 135571. 10.1016/j.chemosphere.2022.135571.35798151
Guberan, E; Usel, M; Raymond, L; Tissot, R; Sweetnam, PM. (1989). Disability, Mortality, and Incidence of Cancer among Geneva Painters and Electricians: A Historical Prospective Study. Br J Ind Med 46: 16–23. 10.1136/oem.46.1.16.2920139
Güerci, A; Seoane, A; Dulout, FN. (2000). Aneugenic effects of some metal compounds assessed by chromosome counting in MRC-5 human cells. Mutat Res 469: 35–40.10946240
Gunaratnam, M; Grant, MH. (2001). Glutathione reductase reduces chromium VI to cytotoxic metabolites in isolated rat hepatocytes [Abstract]. Toxicology 168: 119–121.
Guo, L; Xiao, Y; Wang, Y. (2013a). Hexavalent chromium-induced alteration of proteomic landscape in human skin fibroblast cells. J Proteome Res 12: 3511–3518. 10.1021/pr400375p.23718831
Guo, M; Huang, FQ; Liu, MM; Li, MH. (2013b). Performance of binding interaction between Cr(VI) and serum proteome. Chin J Inorg Chem 29: 1037–1044. 10.3969/j.issn.1001-4861.2013.00.159.
Guo, YJ; Pan, WW; Liu, SB; Shen, ZF; Xu, Y; Hu, LL. (2020). ERK/MAPK signalling pathway and tumorigenesis [Review]. Exp Ther Med 19: 1997–2007. 10.3892/etm.2020.8454.32104259
Guttmann, D; Poage, G; Johnston, T; Zhitkovich, A. (2008). Reduction with glutathione is a weakly mutagenic pathway in chromium(VI) metabolism. Chem Res Toxicol 21: 2188–2194. 10.1021/tx800265g.18808157
Ha, L; Ceryak, S; Patierno, SR. (2004). Generation of S phase-dependent DNA double-strand breaks by Cr(VI) exposure: involvement of ATM in Cr(VI) induction of gamma-H2AX. Carcinogenesis 25: 2265–2274. 10.1093/carcin/bgh242.15284180
Halasova, E; Adamkov, M; Matakova, T; Kavcova, E; Poliacek, I; Singliar, A. (2010). Lung cancer incidence and survival in chromium exposed individuals with respect to expression of antiapoptotic protein survivin and tumor suppressor P53 protein. Eur J Med Res 15: 55–59.21147621
Halasova, E; Matakova, T; Kavcova, E; Musak, L; Letkova, L; Adamkov, M; Ondrusova, M; Bukovska, E; Singliar, A. (2009). Human lung cancer and hexavalent chromium exposure. Neuro Endocrinol Lett 30: 182–185.20027168
Halasova, E; Matakova, T; Musak, L; Polakova, V; Letkova, L; Dobrota, D; Vodicka, P. (2012). Evaluating chromosomal damage in workers exposed to hexavalent chromium and the modulating role of polymorphisms of DNA repair genes. Int Arch Occup Environ Health 85: 473. 10.1007/s00420-011-0684-x.21858514
Halasova, E; Matakova, T; Musak, L; Polakova, V; Vodicka, P. (2008). Chromosomal damage and polymorphisms of DNA repair genes XRCC1 and XRCC3 in workers exposed to chromium. Neuro Endocrinol Lett 29: 658–662.18987609
Halasova, E; Matakova, T; Skerenova, M; Krutakova, M; Slovakova, P; Dzian, A; Javorkova, S; Pec, M; Kypusova, K; Hamzik, J. (2016). Polymorphisms of selected DNA repair genes and lung cancer in chromium exposure. Adv Exp Med Biol 911: 17–22. 10.1007/5584_2016_218.26987333
Hall, A; Kromhout, H; Schüz, J; Peters, S; Portengen, L; Vermeulen, R; Agudo, A; Ahrens, W; Boffetta, P; Brennan, P; Canova, C; Conway, D; Curado, MP; Daudt, AW; Fernandez, L; Hashibe, M, ia; Healy, CM; Holcatova, I; Kjaerheim, K; Koifman, R; Lagiou, P; Luce, D; Macfarlane, GJ; Menezes, A, na; Menvielle, G; Polesel, J; Ramroth, H; Richiardi, L; Stücker, I; Thomson, P; Vilensky, M; Wunsch-Filho, V; Yuan-Chin, A; Znaor, A; Straif, K; Olsson, A. (2020). Laryngeal cancer risks in workers exposed to lung carcinogens: Exposure-effect analyses using a quantitative job exposure matrix. Epidemiology 31: 145–154. 10.1097/EDE.0000000000001120.31577634
Hamilton, JW; Kaltreider, RC; Bajenova, OV; Ihnat, MA; Mccaffrey, J; Turpie, BW; Rowell, EE; Oh, J; Nemeth, MJ; Pesce, CA; Lariviere, JP. (1998). Molecular basis for effects of carcinogenic heavy metals on inducible gene expression. Environ Health Perspect 106: 1005–1015. 10.2307/3434145.9703486
Hanaoka, T; Yamano, Y; Katsuno, N; Kagawa, J; Ishizu, S. (1997). Elevated serum levels of pantropic p53 proteins in chromium workers. Scand J Work Environ Health 23: 37–40. 10.5271/sjweh.176.9098910
Haney, J. (2015a). Consideration of non-linear, non-threshold and threshold approaches for assessing the carcinogenicity of oral exposure to hexavalent chromium. Regul Toxicol Pharmacol 73: 834–852. 10.1016/j.yrtph.2015.10.011.26493004
Haney, J. (2015b). Use of dose-dependent absorption into target tissues to more accurately predict cancer risk at low oral doses of hexavalent chromium. Regul Toxicol Pharmacol 71: 93–100. 10.1016/j.yrtph.2014.11.002.25445295
Haney, J, Jr. (2015c). Implications of dose-dependent target tissue absorption for linear and nonlinear/threshold approaches in development of a cancer-based oral toxicity factor for hexavalent chromium. Regul Toxicol Pharmacol 72: 194–201. 10.1016/j.yrtph.2015.04.015.25910675
Hansen, KS; Lauritsen, IM; Skytthe, A. (1996). Cancer incidence among mild steel and stainless steel welders and other metal workers. Am J Ind Med 30: 373–382. 10.1002/(SICI)097-0274(199610)30:4&lt;373::AID-AJIM1&gt;3.0.CO;2-X.8892541
Hara, T; Hoshuyama, T; Takahashi, K; Delgermaa, V; Sorahan, T. (2010). Cancer risk among Japanese chromium platers, 1976–2003. Scand J Work Environ Health 36: 216–221. 10.5271/sjweh.2889.20024521
Harris, HH; Levina, A; Dillon, CT; Mulyani, I; Lai, B; Cai, Z; Lay, PA. (2005). Time-dependent uptake, distribution and biotransformation of chromium(VI) in individual and bulk human lung cells: application of synchrotron radiation techniques. J Biol Inorg Chem 10: 105–118. 10.1007/s00775-004-0617-1.15714299
Haworth, S; Lawlor, T; Mortelmans, K; Speck, W; Zeiger, E. (1983). Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5: 3–142. 10.1002/em.2860050703.
Havashi, M; Sofuni, T; Ishidate, M. (1982). High-sensitivity in micronucleus induction of a mouse strain (MS). Mutat Res 105: 253–256. 10.1016/0165-7992(82)90038–0.7133031
Hayashi, Y; Kondo, T; Zhao, QL; Ogawa, R; Cui, ZG; Feril, LB; Teranishi, H; Kasuya, M. (2004). Signal transduction of p53-independent apoptotic pathway induced by hexavalent chromium in U937 cells. Toxicol Appl Pharmacol 197: 96–106. 10.1016/j.taap.2004.02.011.15163545
Hayes, RB; Lilienfeld, AM; Snell, LM. (1979). Mortality in chromium chemical production workers: A prospective study. Int J Epidemiol 8: 365–374. 10.1093/ije/8.4.365.541160
Hayes, RB; Sheffet, A; Spirtas, R. (1989). Cancer mortality among a cohort of chromium pigment workers. Am J Ind Med 16: 127–133.2773944
He, F; Ru, X; Wen, T. (2020). NRF2, a transcription factor for stress response and beyond [Review]. International Journal of Molecular Sciences 21: 4777. 10.3390/ijms21134777.32640524
He, J; Qian, X; Carpenter, R; Xu, Q; Wang, L; Qi, Y; Wang, ZX; Liu, LZ; Jiang, BH. (2013). Repression of miR-143 Mediates Cr (VI)-Induced Tumor Angiogenesis via IGF-IR/IRS1/ERK/IL-8 Pathway. Toxicol Sci 134: 26–38. 10.1093/toxsci/kftl01.23748240
Health Canada. (2016). Guidelines for Canadian drinking water quality: Guideline technical document: Chromium. In Guidelines for Canadian Drinking Water Quality. (160192). Ottawa, Ontario: Minister of Health, https://www.canada.ca/en/health-canada/services/environmental-workplace-health/reports-publications/water-quality.html.
Hessel, EVS; Staal, YCM; Piersma, AH; Den Braver-Sewradj, SP; Ezendam, I. (2021). Occupational exposure to hexavalent chromium. Part I. Hazard assessment of non-cancer health effects. Regul Toxicol Pharmacol 126: 105048. 10.1016/j.yrtph.2021.105048.34563613
Hfaiedh, M; Brahmi, D; Zourgui, L. (2014), Protective role of cactus cladodes extract on sodium dichromate-induced testicular injury and oxidative stress in rats. Biol Trace Elem Res 159: 304–311. 10.1007/s12011-014-9969-8.24752970
Hilali, A; Anane, R; Jaaouani, N; Creppy, EE; Verschaeve, L. (2008). Cytogenetic analysis of tannery workers in Morocco. J Appl Toxicol 28: 439–442. 10.1002/jat.1291.17668441
Hill, R; Leidal, AM; Madureira, PA; Gillis, LD; Cochrane, HK; Waisman, DM; Chiu, A; Lee, PWK. (2008a). Hypersensitivity to chromium-induced DNA damage correlates with constitutive deregulation of upstream p53 kinases in p21-/- HCT116 colon cancer cells. DNA Repair 7: 239–252. 10.1016/j.dnarep.2007.10.001.18024214
Hill, R; Leidal, AM; Madureira, PA; Gillis, LD; Waisman, DM; Chiu, A; Lee, PWK. (2008b). Chromium-mediated apoptosis: Involvement of DNA-dependent protein kinase (DNA-PK) and differential induction of p53 target genes. DNA Repair 7: 1484–1499. 10.1016/j.dnarep.2008.05.007.18602874
Hill, WJ; Ferguson, WS. (1979). Statistical analysis of epidemiological data from a chromium chemical manufacturing plant. J Occup Med 21: 103–106. 10.1097/00043764-197902000-00010.430272
Hirose, T; Kondo, K; Takahashi, Y; Ishikura, H; Fujino, H; Tsuyuguchi, M; Hashimoto, M; Yokose, T; Mukai, K; Kodama, T; Monden, Y. (2002). Frequent microsatellite instability in lung cancer from chromate-exposed workers. Mol Carcinog 33: 172–180.11870883
Hjollund, NH; Bonde, JP; Jensen, TK; Henriksen, TB; Andersson, AM; Kolstad, HA; Ernst, E; Giwercman, A; Skakkebaek, NE; Olsen, J. (2000). Male-mediated spontaneous abortion among spouses of stainless steel welders. Scand J Work Environ Health 26: 187–192.10901109
Hodges, NJ; Adám, B; Lee, AJ; Cross, HJ; Chipman, JK. (2001). Induction of DNA-strand breaks in human peripheral blood lymphocytes and A549 lung cells by sodium dichromate: association with 8-oxo-2-deoxyguanosine formation and inter-individual variability. Mutagenesis 16: 467–474. 10.1093/mutage/16.6.467.11682636
Hodges, NJ; Chipman, JK. (2002). Down-regulation of the DNA-repair endonuclease 8-oxo-guanine DNA glycosylase 1 (hOGG1) by sodium dichromate in cultured human A549 lung carcinoma cells. Carcinogenesis 23: 55–60. 10.1093/carcin/23.1.55.11756223
Hodges, NJ; Smart, D; Lee, AJ; Lewis, NA; Chipman, JK. (2004). Activation of c-Jun N-terminal kinase in A549 lung carcinoma cells by sodium dichromate: role of dissociation of apoptosis signal regulating kinase-1 from its physiological inhibitor thioredoxin. Toxicology 197: 101–112. 10.1016/j.tox.2003.12.004.15003321
Hoenig, JM; Heisey, DM. (2001). The abuse of power: The pervasive fallacy of power calculations for data analysis. Am Stat 55: 19–24.
Holmes, AL; Wise, SS; Sandwick, SJ; Lingle, WL; Negron, VC; Thompson, WD; Wise, JP, Sr. (2006a). Chronic exposure to lead chromate causes centrosome abnormalities and aneuploidy in human lung cells. Cancer Res 66: 4041–4048. 10.1158/0008-5472.can-05-3312.16618723
Holmes, AL; Wise, SS; Sandwick, SJ; Wise, JP, Sr. (2006b). The clastogenic effects of chronic exposure to particulate and soluble Cr(VI) in human lung cells. Mutat Res Genet Toxicol Environ Mutagen 610: 8–13. 10.1016/j.mrgentox.2006.06.006.
Hooftman, RN; Arkesteyn, CWM; Roza, P. (1988). Cytotoxicity of some types of welding fume particles to bovine alveolar macrophages. Ann Occup Hyg 32: 95–102. 10.1093/annhyg/32.1.95.3369798
Horiguchi, S; Morinaga, K; Endo, G. (1990). Epidemiological study of mortality from cancer among chromium platers. Asia Pac J Public Health 4: 169–174. 10.1177/101053959000400316.2278768
Hossini, H; Shafie, B; Niri, AD; Nazari, M; Esfahlan, AJ; Ahmadpour, M; Nazmara, Z; Ahmadimanesh, M; Makhdoumi, P; Mirzaei, N; Hoseinzadeh, E. (2022). A comprehensive review on human health effects of chromium: Insights on induced toxicity [Review]. Environ Sci Pollut Res Int 29: 70686–70705. 10.1007/s11356-022-22705-6.36042133
Howe, CG; Nozadi, SS; Garcia, E; O'Connor, TG; Starling, AP; Farzan, SF; Jackson, BP; Madan, JC; Alshawabkeh, AN; Cordero, JF; Bastain, TM; Meeker, JD; Breton, CV; Karagas, MR. (2022). Prenatal metal(loid) mixtures and birth weight for gestational age: A pooled analysis of three cohorts participating in the ECHO program. Environ Int 161: 107102. 10.1016/j.envint.2022.107102.35081493
Hu, G; Feng, H; Long, C; Zhou, D; Li, P; Gao, X; Chen, Z; Wang, T; Jia, G. (2019). LncRNA expression profiling and its relationship with DNA damage in Cr(VI)-treated 16HBE cells. Sci Total Environ 655: 622–632. 10.1016/j.scitotenv.2018.11.074.30476843
Hu, G; Li, P; Cui, X; Li, Y; Zhang, J; Zhai, X; Yu, S; Tang, S; Zhao, Z; Wang, J; Jia, G. (2018). Cr(VI)-induced methylation and down-regulation of DNA repair genes and its association with markers of genetic damage in workers and 16HBE cells. Environ Pollut 238: 833–843. 10.1016/j.envpol.2018.03.046.29627753
Hu, G; Li, P; Li, Y; Wang, T; Gao, X, in; Zhang, W; Jia, G. (2016a). Methylation levels of P16 and TP53 that are involved in DNA strand breakage of 16HBE cells treated by hexavalent chromium. Toxicol Lett 249: 15–21. 10.1016/j.toxlet.2016.03.003.27005777
Hu, G; Liu, J; Zhang, Y; Zheng, P; Wang, L; Zhao, L; Xu, H; Chen, Z; Wang, T; Jia, G. (2016b). Gene expression profiling and bioinformatics analysis in 16HBE cells treated by chromium (VI). Toxicol Lett 264: 71–78. 10.1016/j.toxlet.2016.10.015.27793765
Hu, G; Long, C; Hu, L; Zhang, Y; Hong, S; Zhang, Q; Zheng, P; Su, Z; Xu, J; Wang, L; Gao, X; Zhu, X; Yuan, F; Wang, T; Yu, S; Jia, G. (2022). Blood chromium exposure, immune inflammation and genetic damage: Exploring associations and mediation effects in chromate exposed population. J Hazard Mater 425: 127769. 10.1016/j.jhazmat.2021.127769.34799157
Hu, G; Wang, T; Liu, J; Chen, Z; Zhong, L; Yu, S; Zhao, Z; Zhai, M; Jia, G. (2017). Serum protein expression profiling and bioinformatics analysis in workers occupationally exposed to chromium (VI). Toxicol Lett 277: 76–83. 10.1016/j.toxlet.2017.05.026.28596144
Hu, L; Liu, X; Chervona, Y; Yang, F; Tang, MS; Darzynkiewicz, Z; Dai, W. (2011). Chromium induces chromosomal instability, which is partly due to deregulation of BubR1 and Emi1, two APC/C inhibitors. 10: 2373–2379.
Huang, J; Wu, G; Zeng, R; Wang, J; Cai, R, ui; Ho, JCM, an; Zhang, J; Zheng, Y. (2017). Chromium contributes to human bronchial epithelial cell carcinogenesis by activating Gli2 and inhibiting autophagy. Toxicology Research 6: 324–332. 10.1039/c6tx00372a.30090501
Huang, L; Yu, CH; Hopke, PK; Lioy, PJ; Buckley, BT; Shin, JY; Fan, ZT. (2014). Measurement of soluble and total hexavalent chromium in the ambient airborne particles in New Jersey. Aerosol Air Qual Res 14: 1939–1949. 10.4209/aaqr.2013.10.0312.26120324
Huang, LL; Huang, SF; Luo, XY; Li, LM; Chen, X; Zan, GH; Tan, YL; Liu, CQ; Hou, QZ; Ge, XT; Chen, CF; Hong, X; Tian, Y; Yang, AM; Chen, P; Li, MJ; Mo, ZN; Yang, XB. (2020). Associations of prenatal exposure to multiple metals with testicular volume and anogenital distance in infant boys: A longitudinal cohort study. Environ Int 143: 105900. 10.1016/j.envint.2020.105900.32653800
Huang, YL; Chen, CY; Sheu, JY; Chuang, IC; Pan, JH; Lin, TH. (1999). Lipid peroxidation in workers exposed to hexavalent chromium. J Toxicol Environ Health A 56: 235–247. 10.1080/009841099158088.10706242
Huebner, W; Schoenberg, J; Kelsey, J; Wilcox, H; Mclaughlin, J; Greenberg, R; Preston-Martin, S; Austin, D; Stemhagen, A; Blot, W. (1992). Oral and pharyngeal cancer and occupation: a case-control study. Epidemiology 3: 300–309. 10.1097/00001648-199207000-00005.1637894
Husain, N; Mahmood, R. (2017). Hexavalent chromium induces reactive oxygen species and impairs the antioxidant power of human erythrocytes and lymphocytes: Decreased metal reducing and free radical quenching ability of the cells. Toxicol Ind Health 33: 623–635. 10.1177/0748233717703892.28502229
Husgafvel-Pursiainen, K; Kalliomaki, PL; Sorsa, M. (1982). A chromosome study among stainless steel welders. J Occup Environ Med 24: 762–766.
Huvinen, M. (2002) Exposure to chromium and its long-term health effects in stainless steel production. (Doctoral Dissertation). University of Kuopio, Kuopio, Finnland. Retrieved from http://urn.fi/URN:ISBN:951-781-887-4
Huvinen, M; Mäkitie, A; Järventaus, H; Wolff, H; Stjernvall, T; Hovi, A; Hirvonen, A; Ranta, R; Nurminen, M; Norppa, H. (2002a). Nasal cell micronuclei, cytology and clinical symptoms in stainless steel production workers exposed to chromium. Mutagenesis 17: 425–429. 10.1093/mutage/17.5.425.12202631
Huvinen, M; Pukkala, E. (2013). Cancer incidence among Finnish ferrochromium and stainless steel production workers in 1967–2011: a cohort study. BMJ Open 3: 1–7. 10.1136/bmjopen-2013-003819.
Huvinen, M; Pukkala, E. (2016). Cause-specific mortality in Finnish ferrochromium and stainless steel production workers. Occup Med (Lond) 66: 241–246. 10.1093/occmed/kqv197.26655692
Huvinen, M; Uitti, J; Oksa, P; Palmroos, P; Laippala, P. (2002b). Respiratory health effects of long-term exposure to different chromium species in stainless steel production. Occup Med (Lond) 52: 203–212.12091586
Hydrometrics. (2013). Project report background concentrations of inorganic constituents in Montana surface soils. Helena, MT: Hydrometrics, Inc. https://deq.mt.gov/Portals/112/Land/StateSuperfund/Documents/InorganicBackground/ BkgdInorganicsReport.pdf.
Iaia, TE; Bartoli, D; Calzoni, P; Comba, P; De Santis, M; Dini, F; Ercolanelli, M; Farina, GA; Pirastu, R; Seniori Costantini, A; Valiani, M. (2002). [Cohort study of mortality among leather tanners in the Lower Valdarno area]. Med Lav 93: 95–107.12087805
Iaia, TE; Bartoli, D; Calzoni, P; Comba, P; De Santis, M; Dini, F; Farina, GA; Valiani, M; Pirastu, R. (2006). A cohort mortality study of leather tanners in Tuscany, Italy. Am J Ind Med 49: 452–459. 10.1002/ajim.20309.16586406
IARC (International Agency for Research on Cancer). (1981). Wood, leather and some associated industries. Lyon, France: World Health Orgqanization. http://monographs.iarc.fr/ENG/Monographs/vol25/volume25.pdf.
IARC (International Agency for Research on Cancer). (1990). Chromium, nickel and welding [IARC Monograph]. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol49/index.php.
IARC (International Agency for Research on Cancer). (1998). Some flame retardants and textile chemicals, and exposures in the textile manufacturing industry. Lyon, France.
IARC (International Agency for Research on Cancer). (2010). Painting, firefighting, and shiftwork [IARC Monograph]. In IARC monographs on the evaluation of carcinogenic risks to humans, v 98 (pp. 804-804 pages). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol98/mono98.pdf.
IARC (International Agency for Research on Cancer). (2012). Arsenic, metals, fibres and dusts. IARC monographs on the evaluation of carcinogenic risks to humans, vol. 100C: A review of human carcinogens [IARC Monograph]. Lyon, France: World Health Organization. http://monographs.iarc.fr/ENG/Monographs/vol100C/mono100C.pdf.
IARC (International Agency for Research on Cancer). (2018). Welding, molybdenum trioxide, and indium tin oxide. Lyon, France. https://publications.iarc.fr/_publications/media/download/4890/8dea8d7fcfc96b300786 a8718b69e44475274beb.pdf.
Iarmarcovai, G; Sari-Minodier, I; Chaspoul, F; Botta, C; De Meo, M; Orsiere, T; Berge-Lefranc, JL; Gallice, P; Botta, A. (2005). Risk assessment of welders using analysis of eight metals by ICP-MS in blood and urine and DNA damage evaluation by the comet and micronucleus assays; influence of XRCC1 and XRCC3 polymorphisms. Mutagenesis 20: 425–432. 10.1093/mutage/gei058.16234265
ICRP (International Commission on Radiological Protection). (2002). Basic anatomical and physiological data for use in radiological protection: Reference values (pp. 1–277). (ISSN 0146–645 EISSN 1872–969X ICRP Publication 89). New York, NY: Pergamon Press. 10.1016/S0146-6453(03)00002–2.
ICRP (International Commission on Radiological Protection). (2006). Human alimentary tract model for radiological protection. ICRP Publication 100. A report of The International Commission on Radiological Protection. Ann ICRP 36: 25–327, iii. 10.1016/j.icrp.2006.03.004.17188183
Igarashi, M; Shimada, H. (1997). An improved method for the mouse liver micronucleus test. Mutat Res 391: 49–55. 10.1016/S0165-1218(97)00031–1.9219548
Iijima, S; Spindle, A; Pedersen, RA. (1983). Developmental and cytogenetic effects of potassium dichromate on mouse embryos in vitro. Teratology 27: 109–115. 10.1002/tera.1420270116.6845212
Inada, T; Asai, T; Yamada, M; Shingu, K. (2004). A new method using flow cytometry to measure the effects of drugs on gastric emptying and gastrointestinal transit in mice. Arzneimittelforschung 54: 557–562. 10.1055/s-0031-1297012.15500203
IPCS (International Programme on Chemical Safety). (2007). Harmonization project document no. 4: Part 1: IPCS framework for analysing the relevance of a cancer mode of action for humans and case-studies: Part 2: IPCS framework for analysing the relevance of a non-cancer mode of action for humans. Geneva, Switzerland: World Health Organization. http://www.who.int/ipcs/methods/harmonization/areas/cancer_mode.pdf?ua=1.
Ipcs. (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
IPCS (International Programme on Chemical Safety). (2013). Inorganic chromium(VI) compounds. (78). Geneva, Switzerland: World Health Organization. http://www.who.int/ipcs/publications/cicad/cicad_78.pdf.
Iranmanesh, M; Fatemi, SJ; Ebrahimpour, R; Dahooee Balooch, F. (2013). Chelation of chromium(VI) by combining deferasirox and deferiprone in rats. Biometals 26: 465–471. 10.1007/s10534-013-9631-5.23670101
Ito, S; Schofield, GC. (1974). Studies on the depletion and accumulation of microvilli and changes in the tubulovesicular compartment of mouse parietal cells in relation to gastric acid secretion. J Cell Biol 63: 364–382.4138520
Itoh, S; Shimada, H. (1996). Micronucleus induction by chromium and selenium, and suppression by metallothionein inducer. Mutat Res Genet Toxicol 367: 233–236. 10.1016/S0165-1218(96)90082–8.
Itoh, S; Shimada, H. (1997). Clastogenicity and mutagenicity of hexavalent chromium in lacZ transgenic mice. Toxicol Lett 91: 229–233.9217243
Itoh, S; Shimada, H. (1998). Bone marrow and liver mutagenesis in lacZ transgenic mice treated with hexavalent chromium. Mutat Res 412: 63–67.9508365
Izzotti, A; Bagnasco, M; Camoirano, A; Orlando, M; De Flora, S. (1998). DNA fragmentation, DNA-protein crosslinks, 32P postlabeled nucleotidic modifications, and 8-hydroxy-2'-deoxyguanosine in the lung but not in the liver of rats receiving intratracheal instillations of chromium(VI). Chemoprevention by oral N-acetylcysteine. Mutat Res Fundam Mol Mech Mutagen 400: 233–244. 10.1016/S0027-5107(98)00028–1.
Izzotti, A; Bagnasco, M; Cartiglia, C; Longobardi, M; De Flora, S. (2004). Proteomic analysis as related to transcriptome data in the lung of chromium(VI)-treated rats. Int J Oncol 24: 1513–1522.15138595
Izzotti, A; Cartiglia, C; Balansky, R; D'Agostini, F; Longobardi, M; De Flora, S. (2002). Selective induction of gene expression in rat lung by hexavalent chromium. Mol Carcinog 35: 75–84. 10.1002/mc.10077.12325037
Jacquet, P; Draye, JP. (1982). Toxicity of chromium salts to cultured mouse embryos. Toxicol Lett 12: 53–57. 10.1016/0378-4274(82)90198–9.7112602
Jakobsson, K; Horstmann, V; Welinder, H. (1993). Mortality and cancer morbidity among cement workers. Br J Ind Med 50: 264–272.8457494
Jakobsson, K; Mikoczy, Z; Skerfving, S. (1997). Deaths and tumours among workers grinding stainless steel: a follow up. Occup Environ Med 54: 825–829. 10.1136/oem.54.11.825.9538356
Jannetto, PJ; Antholine, WE; Myers, CR. (2001). Cytochrome b(5) plays a key role in human microsomal chromium(VI) reduction. Toxicology 159: 119–133.11223168
Jansson, C; Oh, JK; Martinsen, JI; Lagergren, J; Plato, N; Kjaerheim, K; Pukkala, E; Sparén, P; Tryggvadottir, L; Weiderpass, E. (2015). Occupation and risk of oesophageal adenocarcinoma and squamous-cell carcinoma: The Nordic Occupational Cancer Study. Int J Cancer 137: 590–597. 10.1002/ijc.29409.25557854
Järvholm, B; Thiringer, G; Axelson, O. (1982). Cancer morbidity among polishers. Br J Ind Med 39: 196–197. 10.1136/oem.39.2.196.7066237
Ji, J; Hemminki, K. (2006). Socio-economic and occupational risk factors for gastric cancer: a cohort study in Sweden. Eur J Cancer Prev 15: 391–397.16912567
Jia, G. (2021). [Request sent to Professor Guang Jia for information from publication with reply, response to request, and follow-up attached]. Available online at (accessed
Jin, Y; Liu, L; Zhang, S; Tao, B; Tao, R; He, X; Qu, L; Huang, J; Wang, X; Fu, Z. (2016). Chromium alters lipopolysaccharide-induced inflammatory responses both in vivo and in vitro. Chemosphere 148: 436–443. 10.1016/j.chemosphere.2016.01.057.26841286
Jin, Y; Zhang, S; Tao, R; Huang, J; He, X; Qu, L; Fu, Z. (2014). Oral exposure of mice to cadmium (II), chromium (VI) and their mixture induce oxidative- and endoplasmic reticulum-stress mediated apoptosis in the livers. Environ Toxicol 31: 693–705. 10.1002/tox.22082.25409916
Johansson, A; Wiernik, A; Jarstrand, C; Camner, P. (1986). Rabbit alveolar macrophages after inhalation of hexa- and trivalent chromium. Environ Res 39: 372–385. 10.1016/S0013-9351(86)80063–9.3956464
Johnson, AJ; Veljanoski, F; O'Doherty, PJ; Zaman, MS; Petersingham, G; Bailey, TD; Münch, G; Kersaitis, C; Wu, MJ. (2016). Revelation of molecular basis for chromium toxicity by phenotypes of Saccharomyces cerevisiae gene deletion mutants. Metallomics 8: 542–550. 10.1039/c6mt00039h.27146641
Johnson, N; Shelton, BJ; Hopenhayn, C; Tucker, TT; Unrine, JM; Huang, B; Christian, WJ; Zhang, Z; Shi, X; Li, L. (2011). Concentrations of arsenic, chromium, and nickel in toenail samples from Appalachian Kentucky residents. J Environ Pathol Toxicol Oncol 30: 213–223. 10.1615/JEnvironPatholToxicolOncol.v30.i3.40.22126614
Joseph, P; He, Q; Umbright, C. (2008). Heme-oxygenase 1 gene expression is a marker for hexavalent chromium-induced stress and toxicity in human dermal fibroblasts. Toxicol Sci 103: 325–334. 10.1093/toxsci/kfn048.18332044
Kaczmarek, M; Timofeeva, OA; Karaczyn, A; Malyguine, A; Kasprzak, KS; Salnikow, K. (2007). The role of ascorbate in the modulation of HIF-1 alpha protein and HIF-dependent transcription by chromium(VI) and nickel(II). Free Radic Biol Med 42: 1246–1257. 10.1016/j.freeradbiomed.2007.01.026.17382205
Kadiiska, MB; Morrow, JD; Awad, JA; Roberts, LJ; Mason, RP. (1998). Identification of free radical formation and F-2-isoprostanes in vivo by acute Cr(VI) poisoning. Chem Res Toxicol 11: 1516–1520. 10.1021/tx980169e.9860496
Kaerlev, L; Teglbjaerg, PS; Sabroe, S; Kolstad, HA; Ahrens, W; Eriksson, M; Gonzalez, AL; Guenel, P; Hardell, L; Launoy, G; Merler, E; Merletti, F; Suarez-Varela, MM; Stang, A. (2000). Occupation and small bowel adenocarcinoma: a European case-control study. Occup Environ Med 57: 760–766. 10.1136/oem.57.11.760.11024200
Kaerlev, L; Teglbjaerg, PS; Sabroe, S; Kolstad, HA; Ahrens, W; Eriksson, M; Guénel, P; Hardell, L; Cyr, D; Ballard, T; Zambon, P; Morales Suárez-Varela, MM; Stang, A; Olsen, J. (2002). Occupational risk factors for small bowel carcinoid tumor: A European population-based case-control study. J Occup Environ Med 44: 516–522.12085477
Kalahasthi, RB; Rao, RH; Murthy, RB; Kumar, MK. (2006). Effect of chromium(VI) on the status of plasma lipid peroxidation and erythrocyte antioxidant enzymes in chromium plating workers. Chem Biol Interact 164: 192–199. 10.1016/j.cbi.2006.09.012.17098216
Kalantzi, L; Goumas, K; Kalioras, V; Abrahamsson, B; Dressman, JB; Reppas, C. (2006). Characterization of the human upper gastrointestinal contents under conditions simulating bioavailability/bioequivalence studies. Pharm Res 23: 165–176. 10.1007/s11095-005-8476-1.16308672
Kalliomäki, PL; Kiilunen, M; Vaaranen, V; Lakomaa, EL; Kalliomäki, K; Kivelä, R. (1982). Retention of stainless steel manual metal arc welding fumes in rats. J Toxicol Environ Health 10: 223–232. 10.1080/15287398209530245.7143476
Kalliomäki, PL; Lakomaa, E; Kalliomäki, K; Kiilunen, M; Kivelä, R; Vaaranen, V. (1983). Stainless steel manual metal arc welding fumes in rats. Br J Ind Med 40: 229–234.6830723
Kaltreider, RC; Pesce, CA; Ihnat, MA; Lariviere, JP; Hamilton, JW. (1999). Differential effects of arsenic(III) and chromium(VI) on nuclear transcription factor binding. Mol Carcinog 25: 219–229. 10.1002/(SICI)1098-2744(199907)25:3<219::AID-MC8>3.0.CO;2-X.10411148
Kanematsu, N; Hara, M; Kada, T. (1980). Rec assay and mutagenicity studies on metal compounds. Mutat Res 77: 109–116. 10.1016/0165-1218(80)90127–5.6769036
Kang, SK; Burnett, CA; Freund, E; Walker, J; Lalich, N; Sestito, J. (1997). Gastrointestinal cancer mortality of workers in occupations with high asbestos exposures. Am J Ind Med 31: 713–718. 10.1002/(sici)1097-0274(199706)31:6<713::aid-ajim7>3.0.co;2-r.9131226
Kano, K; Horikawa, M; Utsunomiya, T; Tati, M; Satoh, K; Yamaguchi, S. (1993). Lung cancer mortality among a cohort of male chromate pigment workers in Japan. Int J Epidemiol 22: 16–22. 10.1093/ije/22.1.16.8449638
Karaulov, AV; Renieri, EA; Smolyagin, AI; Mikhaylova, IV; Stadnikov, AA; Begun, DN; Tsarouhas, K; Buha Djordjevic, A; Hartung, T; Tsatsakis, A. (2019). Long-term effects of chromium on morphological and immunological parameters of Wistar rats. Food Chem Toxicol 133: 110748. 10.1016/j.fct.2019.110748.31377140
Kargacin, B; Squibb, KS; Cosentino, S; Zhitkovich, A; Costa, M. (1993). Comparison of the uptake and distribution of chromate in rats and mice. Biol Trace Elem Res 36: 307–318. 10.1007/BF02783964.
Katabami, M; Dosaka-Akita, H; Mishina, T; Honma, K; Kimura, K; Uchida, Y; Morikawa, K; Mikami, H; Fukuda, S; Inuyama, Y; Ohsaki, Y; Kawakami, Y. (2000). Frequent cyclin D1 expression in chromate-induced lung cancers. Hum Pathol 31: 973–979. 10.1053/hupa.2000.9081.10987259
Kataoka, M; Takashima, T; Shingaki, T; Hashidzume, Y; Katayama, Y; Wada, Y; Oh, H; Masaoka, Y; Sakuma, S; Sugiyama, Y; Yamashita, S; Watanabe, Y. (2012). Dynamic analysis of GI absorption and hepatic distribution processes of telmisartan in rats using positron emission tomography. Pharm Res 29: 2419–2431. 10.1007/s11095-012-0768-7.22618800
Katiyar, S; Awasthi, SK; Sahu, RK. (2008). Suppression of IL-6 level in human peripheral blood mononuclear cells stimulated with PHA/LPS after occupational exposure to chromium. Sci Total Environ 390: 355–361. 10.1016/j.scitotenv.2007.10.031.18031794
Katsiki, M; Trougakos, IP; Chondrogianni, N; Alexopoulos, EC; Makropoulos, V; Gonos, ES. (2004). Alterations of senescence biomarkers in human cells by exposure to CrVI in vivo and in vitro. Exp Gerontol 39: 1079–1087. 10.1016/j.exger.2004.03.039.15236767
Ke, Q; Costa, M. (2007). Overview of Cr(III) toxicity. In JB Vincent (Ed.), The nutritional biochemistry of chromium(III) (pp. 257–263). Amsterdam, Netherlands: Elsevier Science.
Keller, JE; Howe, HL. (1993). Cancer in illinois construction workers: A study. Am J Ind Med 24: 223–230. 10.1002/ajim.4700240208.8213848
Kerger, BD; Finley, BL; Corbett, GE; Dodge, DG; Paustenbach, DJ. (1997). Ingestion of chromium (VI) in drinking water by human volunteers: absorption, distribution, and excretion of single and repeated doses. J Toxicol Environ Health 50: 67–95.9015133
Kerger, BD; Paustenbach, DJ; Corbett, GE; Finley, BL. (1996). Absorption and elimination of trivalent and hexavalent chromium in humans following ingestion of a bolus dose in drinking water. Toxicol Appl Pharmacol 141: 145–158. 10.1006/taap.1996.0271.8917687
Kharab, P; Singh, I. (1985). Genotoxic effects of potassium dichromate, sodium arsenite, cobalt chloride and lead nitrate in diploid yeast. Mutat Res 155: 117–120. 10.1016/0165-1218(85)90128–4.3883155
Kim, H; Cho, SH; Chung, MH. (1999). Exposure to hexavalent chromium does not increase 8-hydroxydeoxyguanosine levels in Korean chromate pigment workers. Ind Health 37: 335–341.10441906
Kim, HY; Lee, SB; Jang, BS. (2004). Subchronic inhalation toxicity of soluble hexavalent chromium trioxide in rats. Arch Toxicol 78: 363–368. 10.1007/s00204-004-0553-4.15205887
Kim, SH; Lee, I, nC; Baek, HS; Moon, C; Kang, SS, oo; Bae, CS, ik; Kim, SH, o; Shin, DH, o; Kim, JC. (2012). Pycnogenol (R) prevents hexavalent chromium-induced spermatotoxicity in rats. Mol Cell Toxicol 8: 249–256. 10.1007/s13273-012-0030-8.
Kim, SJ; Choi, IJ; Cheong, TC; Lee, SJ; Lotan, R; Park, SH; Chun, KH. (2010). Galectin-3 increases gastric cancer cell motility by up-regulating fascin-1 expression. Gastroenterology 138: 1035–1045. 10.1053/j.gastro.2009.09.061.19818782
Kim, SS; Xu, XJ; Zhang, YL; Zheng, XB; Liu, RJ; Dietrich, KN; Reponen, T; Xie, CC; Sucharew, H; Huo, X; Chen, AM. (2020). Birth outcomes associated with maternal exposure to metals from informal electronic waste recycling in Guiyu, China. Environ Int 137: 105580. 10.1016/j.envint.2020.105580.32078870
Kim, YD; An, SC; Oyama, T; Kawamoto, T; Kim, H. (2003). Oxidative stress, hogg1 expression and NF-kappaB activity in cells exposed to low level chromium. J Occup Health 45: 271–277. 10.1539/joh.45.271.14646267
Kirman, CR; Aylward, LL; Suh, M; Harris, MA; Thompson, CM; Haws, LC; Proctor, DM; Lin, SS; Parker, W; Hays, SM. (2013). Physiologically based pharmacokinetic model for humans orally exposed to chromium. Chem Biol Interact 204: 13–27. 10.1016/j.cbi.2013.04.003.23603453
Kirman, CR; Hays, SM; Aylward, LL; Suh, M; Harris, MA; Thompson, CM; Haws, LC; Proctor, DM. (2012). Physiologically based pharmacokinetic model for rats and mice orally exposed to chromium. Chem Biol Interact 200: 45–64. 10.1016/j.cbi.2012.08.016.22981460
Kirman, CR; Suh, M; Hays, SM; Gürleyük, H; Gerads, R; De Flora, S; Parker, W; Lin, S; Haws, LC; Harris, MA; Proctor, DM. (2016). Reduction of hexavalent chromium by fasted and fed human gastric fluid. II. Ex vivo gastric reduction modeling. Toxicol Appl Pharmacol 306: 120–133. 10.1016/j.taap.2016.07.002.27396814
Kirman, CR; Suh, M; Proctor, DM; Hays, SM. (2017). Improved physiologically based pharmacokinetic model for oral exposures to chromium in mice, rats, and humans to address temporal variation and sensitive populations. Toxicol Appl Pharmacol 325: 9–17. 10.1016/j.taap.2017.03.023.28389273
Kitagawa, S; Seki, H; Kametani, F; Sakurai, H. (1982). Uptake of hexavalent chromium by bovine erythrocytes and its interaction with cytoplasmic components; the role of glutathione. Chem Biol Interact 40: 265–274.6282472
Kitamura, F; Yokoyama, K; Araki, S; Nishikitani, M; Choi, JW; Yum, YT; Park, HC; Park, SH; Sato, H. (2003). Increase of olfactory threshold in plating factory workers exposed to chromium in Korea. Ind Health 41: 279–285. 10.2486/indhealth.41.279.12916760
Kitamura, M; Sugamoto, S; Kawauchi, S; Kato, S; Takeuchi, K. (1999). Modulation by endogenous nitric oxide of acid secretion induced by gastric distention in rats: Enhancement by nitric oxide synthase inhibitor. J Pharmacol Exp Ther 291: 181–187.10490902
Klaassen, CD. (2019). Casarett & Doull's toxicology: The basic science of poisons (9th ed.). New York, NY: McGraw Hill.
Klein, CB; Su, L; Bowser, D; Leszczynska, J. (2002). Chromate-induced epimutations in mammalian cells. Environ Health Perspect 110 Suppl 5: 739–743.
Kleinfeld, M; Rosso, A. (1965). Ulcerations of the nasal septum due to inhalation of chromic acid mist. Indian J Med Surg 34: 242–243.
Kneller, RW; Gao, YT; McLaughlin, JK; Gao, RN; Blot, WJ; Liu, MH; Sheng, JP; Fraumeni, JF. (1990). Occupational risk factors for gastric cancer in Shanghai, China. Am J Ind Med 18: 69–78. 10.1002/ajim.4700180108.2378371
Knudsen, I. (1980). The mammalian spot test and its use for the testing of potential carcinogenicity of welding fume particles and hexavalent chromium. Acta Pharmacol Toxicol 47: 66–70. 10.1111/j.1600-0773.1980.tb02027.x.
Koh, DH; Kim, TW; Jang, S; Ryu, HW. (2013). Dust exposure and the risk of cancer in cement industry workers in Korea. Am J Ind Med 56: 276–281. 10.1002/ajim.22132.23109188
Koh, DH; Kim, TW; Jang, SH; Ryu, HW. (2011). Cancer mortality and incidence in cement industry workers in Korea. Saf Health Work 2: 243–249. 10.5491/SHAW.2011.2.3.243.22953208
Kohl, KD; Stengel, A; Samuni-Blank, M; Dearing, MD. (2013). Effects of anatomy and diet on gastrointestinal pH in rodents. J Exp Zool A Ecol Genet Physiol 319: 225–229. 10.1002/jez.1786.23460608
Kondo, K; Hino, N; Sasa, M; Kamamura, Y; Sakiyama, S; Tsuyuguchi, M; Hashimoto, M; Uyama, T; Monden, Y. (1997). Mutations of the p53 gene in human lung cancer from chromate-exposed workers. Biochem Biophys Res Commun 239: 95–100. 10.1006/bbrc.1997.7425.9345276
Kondo, K; Takahashi, Y; Hirose, Y; Nagao, T; Tsuyuguchi, M; Hashimoto, M; Ochiai, A; Monden, Y; Tangoku, A. (2006). The reduced expression and aberrant methylation of p16(INK4a) in chromate workers with lung cancer. Lung Cancer 53: 295–302. 10.1016/j.lungcan.2006.05.022.16828922
Kopec, AK; Kim, S; Forgacs, AL; Zacharewski, TR; Proctor, DM; Harris, MA; Haws, LC; Thompson, CM. (2012a). Genome-wide gene expression effects in B6C3F1 mouse intestinal epithelia following 7 and 90days of exposure to hexavalent chromium in drinking water. Toxicol Appl Pharmacol 259: 13–26. 10.1016/j.taap.2011.11.012.22155349
Kopec, AK; Thompson, CM; Kim, S; Forgacs, AL; Zacharewski, TR. (2012b). Comparative toxicogenomic analysis of oral Cr(VI) exposure effects in rat and mouse small intestinal epithelia. Toxicol Appl Pharmacol 262: 124–138. 10.1016/j.taap.2012.04.026.22561333
Korallus, U; H-J, L; Neiss, A; Zwingers, T. (1982). [Relationships between hygienic measures and the bronchial carcinoma mortality in the chromate producing industry]. Arbeitsmed Sozialmed Praventivmed 17: 159–167.
Korallus, U; Ulm, K; Steinmann-Steiner-Haldenstaett, W. (1993). Bronchial carcinoma mortality in the German chromate-producing industry: the effects of process modification. Int Arch Occup Environ Health 65: 171–178. 10.1007/BF00381153.8282415
Korotzer, B; Ong, S; Hansen, JE. (2000). Ethnic differences in pulmonary function in healthy nonsmoking Asian-Americans and European-Americans. Am J Respir Crit Care Med 161: 1101–1108. 10.1164/ajrccm.161.4.9902063.10764297
Kortenkamp, A; Beyersmann, D; O'Brien, P. (1987). Uptake of chromium (III) complexes by erythrocytes. Toxicol Environ Chem 14: 23–32. 10.1080/02772248709357191.
Koshi, K. (1979). Effects of fume particles from stainless steel welding on sister chromatid exchanges and chromosome aberrations in cultured Chinese hamster cells. Ind Health 17: 39–50. 10.2486/indhealth.17.39.
Koshi, K; Iwasaki, K. (1983). Solubility of low-solubility chromates and their clastogenic activity in cultured cells. Ind Health 21: 57–65. 10.2486/indhealth.21.57.6684105
Koshi, K; Yagami, T; Nakanishi, Y. (1984). Cytogenetic analysis of peripheral blood lymphocytes from stainless steel welders. Ind Health 22: 305–318. 10.2486/indhealth.22.305.6526704
Kost, GC; Patierno, SR; Wise, SS; Holmes, AL; Wise, JP; Ceryak, S. (2012). Protein tyrosine phosphatase (PTP) inhibition enhances chromosomal stability after genotoxic stress: decreased chromosomal instability (CIN) at the expense of enhanced genomic instability (GIN)? Mutat Res 735: 51–55. 10.1016/j.mrfmmm.2012.05.001.22583656
Kotyzova, D; Hodková, A; Bludovská, M; Eybl, V. (2015). Effect of chromium (VI) exposure on antioxidant defense status and trace element homeostasis in acute experiment in rat. Toxicol Ind Health 31: 1044–1050. 10.1177/0748233713487244.23625905
Koutras, GA; Hattori, M; Schneider, AS; Ebaugh, FG; Valentine, WN. (1964). STUDIES ON CHROMATED ERYTHROCYTES. EFFECT OF SODIUM CHROMATE ON ERYTHROCYTE GLUTATHIONE REDUCTASE. J Clin Invest 43: 323–331. 10.1172/JCI104917.14162540
Kraus, JF; Franti, CE; Newman, B. (1982). The utility of regional cancer mortality data for identifying occupations at high risk. Scand J Work Environ Health 8 Suppl 1: 65–71.7100859
Krawic, A; Luczak, M; Zhitkovich, A. (2017). Variation in extracellular detoxification is a link to different carcinogenicity among chromates in rodent and human lungs. Chem Res Toxicol 30: 1720–1729. 10.1021/acs.chemrestox.7b00172.28759204
Krepkiy, D; Antholine, WE; Petering, DH. (2003). Properties of the reaction of chromate with metallothionein. Chem Res Toxicol 16: 750–756. 10.1021/tx020074j.12807358
Krim, M; Messaadia, A; Maidi, I; Aouacheri, O; Saka, S. (2013). Protective effect of ginger against toxicity induced by chromate in rats. Ann Biol Clin (Paris) 71: 165–173. 10.1684/abc.2013.0806.23587580
Krstev, S; Dosemeci, M; Lissowska, J; Chow, WH; Zatonski, W; Ward, MH. (2005). Occupation and risk of stomach cancer in Poland. Occup Environ Med 62: 318–324. 10.1136/oem.2004.015883.15837853
Kumar, A; Rana, SVS. (1982). Lipid accumulation in chromium poisoned rats. Int J Tissue React 4: 291–295.7169300
Kumar, KM; Aruldhas, MM; Banu, SL; Sadasivam, B; Vengatesh, G; Ganesh, KM; Navaneethabalakrishnan, S; Navin, AK; Michael, FM; Venkatachalam, S; Stanley, JA; Ramachandran, I; Banu, SK; Akbarsha, MA. (2017). Male reproductive toxicity of CrVI: In-utero exposure to CrVI at the critical window of testis differentiation represses the expression of Sertoli cell tight junction proteins and hormone receptors in adult F1 progeny rats. Reprod Toxicol 69: 84–98. 10.1016/j.reprotox.2017.02.007.28192182
Kumar, S; Nigam, A; Priya, S; Bajpai, P; Budhwar, R. (2013). Lipoic acid prevents Cr(6+) induced cell transformation and the associated genomic dysregulation. Environ Toxicol Pharmacol 36: 182–193. 10.1016/j.etap.2013.02.016.23608068
Kuo, HW; Chang, SF; Wu, KY; Wu, FY. (2003). Chromium (VI) induced oxidative damage to DNA: increase of urinary 8-hydroxydeoxyguanosine concentrations (8-OHdG) among electroplating workers. Occup Environ Med 60: 590–594.12883020
Kuo, HW; Lai, JS; Lin, TI. (1997). Nasal septum lesions and lung function in workers exposed to chromic acid in electroplating factories. Int Arch Occup Environ Health 70: 272–276.9342628
Kuo, HW; Wu, ML. (2002). Effects of chromic acid exposure on immunological parameters among electroplating workers. Int Arch Occup Environ Health 75: 186–190.11954986
Kusiak, RA; Ritchie, AC; Springer, J; Muller, J. (1993). Mortality from stomach cancer in Ontario miners. Br J Ind Med 50: 117–126. 10.1136/oem.50.2.117.8435344
Kuwahara, Y; Sunagawa, Y; Imoto, Y; Okabe, S. (1990). Effects of orally administered human epidermal growth factor on natural and delayed healing of acetic acid-induced gastric ulcers in rats. Jpn J Pharmacol 52: 164–166. 10.1254/jjp.52.164.2308236
Kuykendall, JR; Kerger, BD; Jarvi, EJ; Corbett, GE; Paustenbach, DJ. (1996). Measurement of DNA-protein cross-links in human leukocytes following acute ingestion of chromium in drinking water. Carcinogenesis 19: 1971–1977. 10.1093/carcin/17.9.1971.
Lai, JS; Kuo, HW; Liao, FC; Lien, CH. (1998). Sister chromatid exchange induced by chromium compounds in human lymphocytes. Int Arch Occup Environ Health 71: 550–553.9860164
Lal, MA; Bae, D; Camilli, TC; Patierno, SR; Ceryak, S. (2009). AKT1 mediates bypass of the G1/S checkpoint after genotoxic stress in normal human cells. 8: 1589–1602.
Langard, S; Andersen, A; Ravnestad, J. (1990). Incidence of cancer among ferrochromium and ferrosilicon workers: an extended observation period. Br J Ind Med 47: 14–19.2310703
Langård, S; Costa, M. (2007). Chromium. In GF Nordberg; BA Fowler; M Nordberg; LT Friberg (Eds.), Handbook on the toxicology of metals (3rd ed., pp. 487–510). Amsterdam, Netherlands: Elsevier. 10.1016/B978-012369413-3/50079-3.
Lanier, B; Kai, G; Marple, B; Wall, GM. (2007). Pathophysiology and progression of nasal septal perforation. Ann Allergy Asthma Immunol 99: 473–480. 10.1016/S1081-1206(10)60373-0.18219827
LaVelle, JM. (1986). Potassium chromate potentiates frameshift mutagenesis in E. coli and S. typhimurium. Mutat Res Genet Toxicol 171: 1–10. 10.1016/0165-1218(86)90002-9.
Le Curieux, F; Marzin, D; Erb, F. (1993). Comparison of three short-term assays: Results on seven chemicals. Potential contribution to the control of water genotoxicity. Mutat Res 319: 223–236. 10.1016/0165-1218(93)90082-O.7694144
Lee, AJ; Hodges, NJ; Chipman, JK. (2004). Modified comet assay as a biomarker of sodium dichromate-induced oxidative DNA damage: Optimization and reproducibility. Biomarkers 9: 103–115. 10.1080/13547500410001704891.15370870
Lee, AJ; Hodges, NJ; Chipman, JK. (2005). Interindividual variability in response to sodium dichromate-induced oxidative DNA damage: role of the Ser326Cys polymorphism in the DNA-repair protein of 8-oxo-7,8-dihydro-2'-deoxyguanosine DNA glycosylase 1. Cancer Epidemiol Biomarkers Prev 14: 497–505. 10.1158/1055-9965.EPI-04-0295.15734978
Lee, HS; Goh, CL. (1988). Occupational dermatosis among chrome platers. Contact Derm 18: 89–93. 10.1111/j.1600-0536.1988.tb02746.x.
Lee, YH; Su, SB; Huang, CC; Sheu, HM; Tsai, JC; Lin, CH; Wang, YJ; Wang, BJ. (2014). N-acetylcysteine attenuates hexavalent chromium-induced hypersensitivity through inhibition of cell death, ROS-related signaling and cytokine expression. PLoS ONE 9: e108317. 10.1371/journal.pone.0108317.25248126
Leese, E; Jones, K; Bocca, B; Bousoumah, R; Castaño, A; Galea, KS; Iavicoli, I; López, ME; Leso, V; Ndaw, S; Porras, SP; Ruggieri, F; Scheepers, PTJ; Santonen, T. (2023). HBM4EU chromates study – The measurement of hexavalent and trivalent chromium in exhaled breath condensate samples from occupationally exposed workers across Europe. Toxicol Lett 375: 59–68. 10.1016/j.toxlet.2022.12.009.36535516
Lei, T; He, QY; Cai, Z; Zhou, Y; Wang, YL; Si, LS; Cai, Z; Chiu, JF. (2008). Proteomic analysis of chromium cytotoxicity in cultured rat lung epithelial cells. Proteomics 8: 2420–2429. 10.1002/pmic.200701050.18563748
Levina, A; Harris, HH; Lay, PA. (2007). X-ray absorption and EPR spectroscopic studies of the biotransformations of chromium(VI) in mammalian cells. Is chromodulin an artifact of isolation methods? J Am Chem Soc 129: 1065–1075. 10.1021/ja063792r.17263387
Levina, A; Zhang, L; Lay, PA. (2010). Formation and reactivity of chromium(V)-thiolato complexes: a model for the intracellular reactions of carcinogenic chromium(VI) with biological thiols. J Am Chem Soc 132: 8720–8731. 10.1021/ja101675w.20527748
Levis, AG; Majone, F. (1979). Cytotoxic and clastogenic effects of soluble chromium compounds on mammalian cell cultures. Br J Cancer 40: 523–533.497104
Lewalter, J; Korallus, U. (1989). The significance of ascorbic acid and glutathione for chromate metabolism in man. Toxicol Environ Chem 24: 25–33. 10.1080/02772248909357474.
Li, LT; Jiang, G; Chen, Q; Zheng, JN. (2015a). Ki67 is a promising molecular target in the diagnosis of cancer [Review]. Mol Med Rep 11: 1566–1572. 10.3892/mmr.2014.2914.25384676
Li, P; Gu, Y; Yu, S; Li, Y; Yang, J; Jia, G. (2014a). Assessing the suitability of 8-OHdG and micronuclei as genotoxic biomarkers in chromate-exposed workers: a cross-sectional study. BMJ Open 4: e005979. 10.1136/bmjopen-2014-005979.
Li, P; Li, Y; Zhang, J, i; Yu, SF, a; Tong, W, ei; Hu, X; Jia, G. (2015b). Biomarkers for Lung Epithelium Injury in Occupational Hexavalent Chromium-Exposed Workers. J Occup Environ Med 57: E45–E50. 10.1097/JOM.0000000000000436.25851191
Li, Y; Hu, G; Li, P; Tang, S; Zhang, J; Jia, G. (2016). miR-3940–5p enhances homologous recombination after DSB in Cr(VI) exposed 16HBE cell. Toxicology 344-346: 1–6. 10.1016/j.tox.2016.02.003.
Li, Y; Li, P; Yu, S; Zhang, J; Wang, T; Jia, G. (2014b). miR-3940–5p associated with genetic damage in workers exposed to hexavalent chromium. Toxicol Lett 229: 319–326. 10.1016/j.toxlet.2014.06.033.24973494
Liang, Q; Xiao, Y; Liu, K; Zhong, C; Zeng, M; Xiao, F. (2018). Cr(VI)-induced autophagy protects L-02 hepatocytes from apoptosis through the ROS-AKT-mTOR pathway. Cell Physiol Biochem 51: 1863–1878. 10.1159/000495713.30504711
Liang, Q; Zhang, Y; Huang, M; Xiao, Y; Xiao, F. (2019). Role of mitochondrial damage in Cr(VI)‑induced endoplasmic reticulum stress in L‑02 hepatocytes. Mol Med Rep 19: 1256–1265. 10.3892/mmr.2018.9704.30535451
Lin, SC; Tai, CC; Chan, CC; Wang, JD. (1994). Nasal septum lesions caused by chromium exposure among chromium electroplating workers. Am J Ind Med 26: 221–228. 10.1002/ajim.4700260207.7977397
Lin, X; Zhuang, Z; Costa, M. (1992). Analysis of residual amino acid–DNA crosslinks induced in intact cells by nickel and chromium compounds. Carcinogenesis 13: 1763–1768. 10.1093/carcin/13.10.1763.1423835
Lindberg, E; Hedenstierna, G. (1983). Chrome plating: Symptoms, findings in the upper airways, and effects on lung function. Arch Environ Occup Health 38: 367–374.
Lindemann, M; Rietschel, F; Zabel, M; Grosse-Wilde, H. (2008). Detection of chromium allergy by cellular in vitro methods. Clin Exp Allergy 38: 1468–1475. 10.1111/j.1365-2222.2008.02970.x.18384428
Lindsay, JP; Stavraky, KM; Howe, GR. (1993). The Canadian Labour Force Ten Percent Sample Study. Cancer mortality among men, 1965–1979. J Occup Med 35: 408–414.8487120
Linos, A; Petralias, A; Christophi, CA; Christoforidou, E; Kouroutou, P; Stoltidis, M; Veloudaki, A; Tzala, E; Makris, KC; Karagas, MR. (2011). Oral ingestion of hexavalent chromium through drinking water and cancer mortality in an industrial area of Greece--an ecological study. Environ Health 10: 50. 10.1186/1476-069X-10-50.21609468
Linqing, Y; Bo, X; Xueqin, Y; Hong, D; Desheng, W; Huimin, Z; Gaofeng, J; Jianjun, L; Zhixiong, Z. (2016). Mitochondrial DNA hypomethylation in chrome plating workers. Toxicol Lett 243: 1–6. 10.1016/j.toxlet.2015.11.031.26656300
Lipworth, L; Sonderman, JS; Mumma, MT; Tarone, RE; Marano, DE; Boice, JD; McLaughlin, JK. (2011). Cancer mortality among aircraft manufacturing workers: An extended follow-up. J Occup Environ Med 53: 992–1007. 10.1097/JOM.0b013e31822e0940.21866047
listed, Na. (1988). Strain difference in the micronucleus test. The Collaborative Study Group for the Micronucleus Test. Mutat Res 204: 307–316. 10.1016/0165-1218(88)90104-8.3343980
Littorin, M; Hogstedt, B; Stromback, B; Karlsson, A; Welinder, H; Mitelman, F; Skerfving, S. (1983). No cytogenetic effects in lymphocytes of stainless steel welders. Scand J Work Environ Health 9: 259–264.6612267
Liu, C; Song, C; Li, J; Sun, Q. (2020). CFTR functions as a tumor suppressor and is regulated by DNA methylation in colorectal cancer. Cancer Management and Research 12: 4261—4270. 10.2147/CMAR.S248539.32606923
Liu, FJ; Barchowsky, A; Opresko, PL. (2009). The Werner syndrome protein functions in repair of Cr(VI)-induced replication-associated DNA damage. Toxicol Sci 110: 307–318. 10.1093/toxsci/kfp104.19487340
Liu, FJ; Barchowsky, A; Opresko, PL. (2010a). The Werner syndrome protein suppresses telomeric instability caused by chromium (VI) induced DNA replication stress. PLoS ONE 5: e11152. 10.1371/journal.pone.0011152.20585393
Liu, KJ; Jiang, J; Swartz, HM; Shi, X. (1994). Low-frequency EPR detection of chromium(V) formation by chromium(VI) reduction in whole live mice. Arch Biochem Biophys 313: 248–252.8080269
Liu, KJ; Mäder, K; Shi, X; Swartz, HM. (1997). Reduction of carcinogenic chromium(VI) on the skin of living rats. Magn Reson Med 38: 524–526. 10.1002/mrm.1910380403.9324316
Liu, KJ; Shi, X; Jiang, J; Goda, F; Dalal, N; Swartz, HM. (1996). Low frequency electron paramagnetic resonance investigation on metabolism of chromium (VI) by whole live mice. Ann Clin Lab Sci 26: 176–184.8852427
Liu, W; Chaspoul, F; Botta, C; De Méo, M; Gallice, P. (2010b). Bioenergetics and DNA alteration of normal human fibroblasts by hexavalent chromium. Environ Toxicol Pharmacol 29: 58–63. 10.1016/j.etap.2009.10.001.21787583
Lizarraga, LE; Suter, GW; Lambert, JC; Patlewicz, G; Zhao, JQ; Dean, JL; Kaiser, P. (2023). Advancing the science of a read-across framework for evaluation of data-poor chemicals incorporating systematic and new approach methods. Regul Toxicol Pharmacol 137: 105293. 10.1016/j.yrtph.2022.105293.36414101
Llagostera, M; Garrido, S; Guerrero, R; Barbé, J. (1986). Induction of SOS genes of Escherichia coli by chromium compounds. Environ Mutagen 8: 571–577. 10.1002/em.2860080408.3525136
Long, C; Liu, J; Hu, G; Feng, H; Zhou, D; Wang, J; Zhai, X; Zhao, Z; Yu, S; Wang, T; Jia, G. (2019). Modulation of homologous recombination repair gene polymorphisms on genetic damage in chromate exposed workers. Environ Toxicol Pharmacol 66: 126–132. 10.1016/j.etap.2019.01.004.30677706
Lou, J; Wang, Y; Chen, J; Ju, L; Yu, M; Jiang, Z; Feng, L; Jin, L; Zhang, X. (2015). Effects of soluble and particulate Cr(VI) on genome-wide DNA methylation in human B lymphoblastoid cells. Mutat Res Genet Toxicol Environ Mutagen 792: 12–18. 10.1016/j.mrgentox.2015.08.004.26433257
Lozsekova, A; Kaiser, HW; Danilla, T; Buchvald, J; Simko, J. (2002). The effect of nickel sulphate, potassium dichromate, cobalt nitrate and cadmium sulphate on the proteins of cellular contacts and actin skeleton of cultivated human keratinocytes. Bratisl Lek Listy 103: 254–259.12518998
Lu, J; Tang, M; Liu, Y; Wang, J; Wu, Z. (2018a). Comparative Proteomics of Chromium-Transformed Beas-2B Cells by 2D-DIGE and MALDI-TOF/TOF MS. Biol Trace Elem Res. 10.1007/s12011-017-1222-9.
Lu, J; Zhou, Z; Tang, M; Shen, H; Liu, Y; Wang, J; Jiang, Y; Chen, Y; Wu, Z. (2018b). Role of LKB1 in migration and invasion of Cr(VI)-transformed human bronchial epithelial Beas-2B cells. Anticancer Drugs 29: 660–673. 10.1097/CAD.0000000000000638.29782351
Lucas, JB. (1976). Health Hazard Evaluation Determination, Report No. HHE-74–111-283, Cook Paint and Varnish Company, North Kansas City, Missouri, April 1976 (pp. 74–111). (NIOSH/00099446). Lucas, JB.
Lucas, JB; Kramkowski, RS. (1975). Health Hazard Evaluation Report No. HHE-74–87-221, Industrial Platers, Inc., Columbus, Ohio (pp. 74–87). (NIOSH/00049983). Cincinnati, OH: National Inst. for Occupational Safety and Health.
Luczak, MW; Green, SE; Zhitkovich, A. (2016). Different ATM Signaling in Response to Chromium(VI) Metabolism via Ascorbate and Nonascorbate Reduction: Implications for in Vitro Models and Toxicogenomics. Environ Health Perspect 124: 61–66. 10.1289/ehp.1409434.25977998
Luippold, RS; Mundt, KA; Austin, RP; Liebig, E; Panko, J; Crump, C; Crump, K; Proctor, D. (2003). Lung cancer mortality among chromate production workers. Occup Environ Med 60: 451–457.12771398
Luippold, RS; Mundt, KA; Dell, LD; Birk, T. (2005). Low-level hexavalent chromium exposure and rate of mortality among US chromate production employees. J Occup Environ Med 47: 381–385. 10.1097/01.jom.0000158703.32263.0d.15824629
Lukanova, A; Toniolo, P; Zhitkovich, A; Nikolova, V; Panev, T; Popov, T; Taioli, E; Costa, M. (1996). Occupational exposure to Cr(VI): comparison between chromium levels in lymphocytes, erythrocytes, and urine. Int Arch Occup Environ Health 69: 39–44.9017433
Luo, D; Xu, Z; Hu, X; Zhang, F; Bian, H; Li, N; Wang, Q; Lu, Y; Zheng, Q; Gu, J. (2016). URI prevents potassium dichromate-induced oxidative stress and cell death in gastric cancer cells. 8: 5399–5409.
Lupescu, A; Jilani, K; Zelenak, C; Zbidah, M; Qadri, SM; Lang, F. (2012). Hexavalent chromium-induced erythrocyte membrane phospholipid asymmetry. Biometals 25: 309–318. 10.1007/s10534-011-9507-5.22080200
Lv, Y; Zhang, P; Guo, J; Zhu, Z; Li, X; Xu, D; Zeng, W. (2018). Melatonin protects mouse spermatogonial stem cells against hexavalent chromium-induced apoptosis and epigenetic histone modification. Toxicol Appl Pharmacol 340: 30–38. 10.1016/j.taap.2017.12.017.29289671
Lynge, E; Rix, BA; Villadsen, E; Andersen, I; Hink, M; Olsen, E; Møller, UL; Silfverberg, E. (1995). Cancer in printing workers in Denmark. Occup Environ Med 52: 738–744. 10.1136/oem.52.11.738.8535493
Ma, F; Zhang, Z; Jiang, J; Hu, J. (2015). Chromium (VI) potentiates the DNA adducts (O(6)-methylguanine) formation of N-nitrosodimethylamine in rat: implication on carcinogenic risk. Chemosphere 139: 256–259. 10.1016/j.chemosphere.2015.06.077.26143543
Macfie, A; Hagan, E; Zhitkovich, A. (2010). Mechanism of DNA-protein cross-linking by chromium. Chem Res Toxicol 23: 341–347. 10.1021/tx9003402.19877617
Machle, W; Gregorius, F. (1948). Cancer of the respiratory system in the United States chromate-producing industry. Public Health Rep 63: 1114–1127. 10.2307/4586677.18878263
MacKenzie, RD; Anwar, RA; Byerrum, RU; Hoppert, CA. (1959). Absorption and distribution of Cr51 in the albino rat. Arch Biochem Biophys 79: 200–205. 10.1016/0003-9861(59)90396-0.
MacKenzie, RD; Byerrum, RU; Decker, CF; Hoppert, CA; Langham, RF. (1958). Chronic toxicity studies. II. Hexavalent and trivalent chromium administered in drinking water to rats. AMA Arch Ind Health 18: 232–234.13570713
Macleod, JS; Harris, MA; Tjepkema, M; Peters, PA; Demers, PA. (2017). Cancer risks among welders and occasional welders in a national population-based cohort study: Canadian census health and environmental cohort. Saf Health Work 8: 258–266. 10.1016/j.shaw.2016.12.001.28951802
Macrae, WD; Whiting, RF; Stich, HF. (1979). Sister chromatid exchanges induced in cultured mammalian cells by chromate. Chem Biol Interact 26: 281–286.509691
Madejczyk, MS; Baer, CE; Dennis, WE; Minarchick, VC; Leonard, SS; Jackson, DA; Stallings, JD; Lewis, JA. (2015). Temporal changes in rat liver gene expression after acute cadmium and chromium exposure. PLoS ONE 10: e0127327. 10.1371/journal.pone.0127327.25993096
Maeng, SH; Chung, HW; Kim, KJ; Lee, BM; Shin YC Kim, SJ; Yu, IJ. (2004). Chromosome aberration and lipid peroxidation in chromium-exposed workers. Biomarkers 9: 418–434. 10.1080/13547500400022200.15849063
Maeng, SH; Chung, HW; Yu, IJ; Kim, HY; Lim, CH; Kim, KJ; Kim, SJ; Ootsuyama, Y; Kasai, H. (2003). Changes of 8-OH-dG levels in DNA and its base excision repair activity in rat lungs after inhalation exposure to hexavalent chromium. Mutat Res 539: 109–116. 10.1016/S1383-5718(03)00154-2.12948819
Mahiout, S; Kiilunen, M; Vermeire, T; Viegas, S; Woutersen, M; Santonen, T. (2022). Occupational exposure to Cr(VI) in Finland in 1980–2016 and related lung cancer risk assessment. Regul Toxicol Pharmacol 136: 105276. 10.1016/j.yrtph.2022.105276.36240957
Majone, F; Levis, AG. (1979). Chromosomal aberrations and sister-chromatid exchanges in Chinese hamster cells treated in vitro with hexavalent chromium compounds. Mutat Res Genet Toxicol 67: 231–238. 10.1016/0165-1218(79)90017-X.
Majumder, S; Ghoshal, K; Summers, D; Bai, S; Datta, J; Jacob, ST. (2003). Chromium(VI) down-regulates heavy metal-induced metallothionein gene transcription by modifying transactivation potential of the key transcription factor, metal-responsive transcription factor 1. J Biol Chem 278: 26216–26226. 10.1074/jbc.M302887200.12716893
Malker, HS; Gemne, G. (1987). A register-epidemiology study on cancer among Swedish printing industry workers. Arch Environ Health 42: 73–82. 10.1080/00039896.1987.9935799.3579369
Mallin, K; Rubin, M; Joo, E. (1989). Occupational cancer mortality in Illinois white and black males, 1979–1984, for seven cancer sites. Am J Ind Med 15: 699–717.2665480
Malsch, PA; Proctor, DM; Finley, BL. (1994). Estimation of a chromium inhalation reference concentration using the benchmark dose method: A case study [Review]. Regul Toxicol Pharmacol 20: 58–82. 10.1006/rtph.1994.1036.7838992
Mancuso, TF. (1951). Occupational cancer and other health hazards in a chromate plant: A medical appraisal. II. Clinical and toxicologic aspects. Ind Med Surg 20: 393–407.14860912
Mancuso, TF. (1975). Consideration of chromium as an industrial carcinogen. In International conference on heavy metals in the environment: v III, health; October. Toronto, ON, Canada: Institute for Environmental Studies.
Mancuso, TF. (1997). Chromium as an industrial carcinogen: Part I. Am J Ind Med 31: 129–139. 10.1002/(SICI)1097-0274(199702)31:2<129::AID-AJIM1>3.0.CO;2-V.9028428
Mancuso, TF; Hueper, WC. (1951). Occupational cancer and other health hazards in a chromate plant: a medical appraisal I Lung cancers in chromate workers. Indian J Med Surg 20: 358–363.
Manzo, L; Di Nucci, A; Edel, J; Gregotti, C; Sabbioni, E. (1983). Biliary and gastrointestinal excretion of chromium after administration of Cr-III and Cr-VI in rats. Res Commun Mol Pathol Pharmacol 42: 113–125.
Marat, I; Arstan, M; Galymzhan, Y; Timur, J; Yerbolat, I; Almasbek, Y. (2018). Impact of chromium and boron compounds on the reproductive function in rats. Toxicol Ind Health 34: 365–374. 10.1177/0748233718759162.29591889
Marouani, N; Tebourbi, O; Hallègue, D; Mokni, M; Yacoubi, MT; Sakly, M; Benkhalifa, M; Rhouma, KB. (2015a). Mechanisms of chromium hexavalent-induced apoptosis in rat testes. Toxicol Ind Health 33: 97–106. 10.1177/0748233715600333.
Marouani, N; Tebourbi, O; Mahjoub, S; Yacoubi, MT; Sakly, M; Benkhalifa, M; Rhouma, KB. (2012). Effects of hexavalent chromium on reproductive functions of male adult rats. Reprod Biol 12: 119–133.22850466
Marouani, N; Tebourbi, O; Mokni, M; Yacoubi, MT; Sakly, M; Benkhalifa, M; Ben Rhouma, K. (2015b). Hexavalent chromium-induced apoptosis in rat uterus: Involvement of oxidative stress. Arch Environ Occup Health 70: 189–195. 10.1080/19338244.2013.828673.24965329
Martin, BD; Schoenhard, JA; Hwang, JM; Sugden, KD. (2006). Ascorbate is a pro-oxidant in chromium-treated human lung cells. Mutat Res 610: 74–84. 10.1016/j.mrgentox.2006.06.014.16857421
Martin Remy, A; Robert, A; Jacoby, N; Wild, P. (2021). Is Urinary Chromium Specific to Hexavalent Chromium Exposure in the Presence of Co-exposure to Other Chromium Compounds? A Biomonitoring Study in the Electroplating Industry. Ann Work Expo Health 65: 332–345. 10.1093/annweh/wxaa107.
Martino, J; Holmes, AL; Xie, H; Wise, SS; Wise, JP. (2015). Chronic Exposure to Particulate Chromate Induces Premature Centrosome Separation and Centriole Disengagement in Human Lung Cells. Toxicol Sci 147: 490–499. 10.1093/toxsci/kfv146.26293554
Marzin, DR; Phi, HV. (1985). Study of the mutagenicity of metal derivatives with Salmonella typhimurium TA102. Mutat Res 155: 49–51. 10.1016/0165-1218(85)90024-2.3881664
Mastrangelo, G; Fedeli, U; Fadda, E; Milan, G; Lange, JH. (2002). Epidemiologic evidence of cancer risk in textile industry workers: a review and update. Toxicol Ind Health 18: 171–181. 10.1191/0748233702th139rr.12974540
Matanoski, GM; Stockwell, HG; Diamond, EL; Haring-Sweeney, M; Joffe, RD; Mele, LM; Johnson, ML. (1986). A cohort mortality study of painters and allied tradesmen. Scand J Work Environ Health 12: 16–21.3961437
Matsui, S. (1980). Evaluation of a Bacillus subtilis recombination-assay for the detection of mutagens which may occur in water environments. Water Res 14: 1613–1620.
Mattagajasingh, SN; Misra, BR; Misra, HP. (2008). Carcinogenic chromium(VI)-induced protein oxidation and lipid peroxidation: implications in DNA-protein crosslinking. J Appl Toxicol 28: 987–997. 10.1002/jat.1364.18615841
Mattagajasingh, SN; Misra, HP. (1995). Alterations in the prooxidant and antioxidant status of human leukemic T-lymphocyte MOLT4 cells treated with potassium chromate. Mol Cell Biochem 142: 61–70. 10.1007/BF00928914.7753043
Mattagajasingh, SN; Misra, HP. (1996). Mechanisms of the carcinogenic chromium(VI)-induced DNA-protein cross-linking and their characterization in cultured intact human cells. J Biol Chem 271: 33550–33560.8969221
Mattagajasingh, SN; Misra, HP. (1997). Carcinogenic chromium(VI) induces oxidative stress in cultured human leukemic T-lymphocytes. 1. Generation of hydrogen peroxide during intracellular reduction of chromate. Toxic Subst Mech 16: 63–79.
Mccarroll, N; Keshava, N; Chen, J; Akerman, G; Kligerman, A; Rinde, E. (2010). An evaluation of the mode of action framework for mutagenic carcinogens case study II: chromium (VI) [Review]. Environ Mol Mutagen 51: 89–111. 10.1002/em.20525.19708067
Mcconnell, EL; Basit, AW; Murdan, S. (2008). Measurements of rat and mouse gastrointestinal pH, fluid and lymphoid tissue, and implications for in-vivo experiments. J Pharm Pharmacol 60: 63–70. 10.1211/jpp.60.1.0008.18088506
Mcdowall, ME. (1984). A mortality study of cement workers. Br J Ind Med 41: 179–182. 10.1136/oem.41.2.179.6562903
Mcgregor, DB; Martin, R; Cattanach, P; Edwards, I; Mcbride, D; Caspary, WJ. (1987). Responses of the L5178Y tk+/tk- mouse lymphoma cell forward mutation assay to coded chemicals. I: Results for nine compounds. Environ Mutagen 9: 143–160. 10.1002/em.2860090205.3102223
Mcmillan, GH; Pethybridge, RJ. (1983). The health of welders in naval dockyards: proportional mortality study of welders and two control groups. J Soc Occup Med 33: 75–84. 10.1093/occmed/33.2.75.6865346
Medan, D; Luanpitpong, S; Azad, N; Wang, L; Jiang, BH; Davis, ME; Barnett, JB; Guo, L; Rojanasakul, Y. (2012). Multifunctional Role of Bcl-2 in Malignant Transformation and Tumorigenesis of Cr(VI)-Transformed Lung Cells. PLoS ONE 7: e37045. 10.1371/journal.pone.0037045.22666341
Medeiros, MG; Rodrigues, AS; Batoréu, MC; Laires, A; Rueff, J; Zhitkovich, A. (2003). Elevated levels of DNA-protein crosslinks and micronuclei in peripheral lymphocytes of tannery workers exposed to trivalent chromium. Mutagenesis 18: 19–24.12473731
Meek, ME; Bucher, J. R.; Cohen, SM; Dellarco, V; Hill, RN; Lehman-Mckeeman, LD; Longfellow, DG; Pastoor, T; Seed, J; Patton, DE. (2003). A framework for human relevance analysis of information on carcinogenic modes of action [Review]. Crit Rev Toxicol 33: 591–653. 10.1080/713608373.14727733
Melkild, A; Langård, S; Andersen, A; Tønnessen, JN. (1989). Incidence of cancer among welders and other workers in a Norwegian shipyard. Scand J Work Environ Health 15: 387–394. 10.5271/sjweh.1834.2617255
Merk, O; Reiser, K; Speit, G. (2000). Analysis of chromate-induced DNA-protein crosslinks with the comet assay. Mutat Res 471: 71–80. 10.1016/s1383-5718(00)00110-8.11080662
Merritt, K; Brown, SA; Sharkey, NA. (1984). The binding of metal salts and corrosion products to cells and proteins in vitro. J Biomed Mater Res 18: 1005–1015. 10.1002/jbm.820180905.6544790
Merritt, K; Crowe, TD; Brown, SA. (1989). Elimination of nickel, cobalt, and chromium following repeated injections of high dose metal salts. J Biomed Mater Res 23: 845–862. 10.1002/jbm.820230804.2777829
Mertz, W; Roginski, EE; Feldman, FJ; Thurman, DE. (1969). Dependence of chromium transfer into the rat embryo on the chemical form. J Nutr 99: 363–367.5350992
Mezencev, R; Auerbach, SS. (2021). Inferred inactivation of the Cftr gene in the duodena of mice exposed to hexavalent chromium (Cr(VI)) in drinking water supports its tumor-suppressor status and implies its potential role in Cr(VI)-induced carcinogenesis of the small intestines. Toxicol Appl Pharmacol 433: 115773. 10.1016/j.taap.2021.115773.34688701
Mezencev, R; Gibbons, C. (2023). Interactions between chromium species and DNA in vitro and their potential role in the toxicity of hexavalent chromium. Metallomics 15. 10.1093/mtomcs/mfad045.
Migliore, L; Parrini, M; Sbrana, I; Biagini, C; A; Loprieno, N. (1991). Micronucleated lymphocytes in people occupationally exposed to potential environmental contaminants: The age effect. Mutat Res 256: 13–20. doi:10.1016/0921-8734(91)90028-A.1944383
Mignini, F; Streccioni, V; Baldo, M; Vitali, M; Indraccolo, U; Bernacchia, G; Cocchioni, M. (2004). Individual susceptibility to hexavalent chromium of workers of shoe, hide, and leather industries. Immunological pattern of HLA-B8, DR3-positive subjects. Prev Med 39: 767–775. 10.1016/j.ypmed.2004.02.048.15351544
Mignini, F; Tomassoni, D; Traini, E; Vitali, M; Scuri, S; Baldoni, E; Grappasonni, I; Cocchioni, M. (2009). Immunological pattern alteration in shoe, hide, and leather industry workers exposed to hexavalent chromium. Environ Toxicol 24: 594–602. 10.1002/tox.20464.19051261
Mikalsen, A; Alexander, J; Ryberg, D. (1989). Microsomal metabolism of hexavalent chromium Inhibitory effect of oxygen and involvement of cytochrome P-450. Chem Biol Interact 69: 175–192.2495190
Mikalsen, A; Alexander, J; Wallin, H; Ingelman-Sundberg, M; Andersen, RA. (1991). Reductive metabolism and protein binding of chromium(VI) by P450 protein enzymes. Carcinogenesis 12: 825–831. 10.1093/carcin/12.5.825.1903091
Mikoczy, Z; Hagmar, L. (2005). Cancer incidence in the Swedish leather tanning industry: updated findings 1958–99. Occup Environ Med 62: 461–464. 10.1136/oem.2004.017038.15961622
Mikoczy, Z; Schütz, A; Hagmar, L. (1994). Cancer incidence and mortality among Swedish leather tanners. Occup Environ Med 51: 530–535. 10.1136/oem.51.8.530.7951777
Miksche, LW; Lewalter, J. (1995). Biological monitoring of exposure to hexavalent chromium in isolated erythrocytes. In Biomarkers and Occupational Health:: Progress and Perspectives. Washington, DC: National Academies Press. http://www.nap.edu/catalog.php?record_id=4924.
Milatou-Smith, R; Gustavsson, A; Sjögren, B. (1997). Mortality among welders exposed to high and to low levels of hexavalent chromium and followed for more than 20 Years. Int J Occup Environ Health 3: 128–131.9891110
Miller, AC; Comellas, AP; Hornick, DB; Stoltz, DA; Cavanaugh, JE; Gerke, AK; Welsh, MJ; Zabner, J; Polgreen, PM. (2020). Cystic fibrosis carriers are at increased risk for a wide range of cystic fibrosis-related conditions. Proc Natl Acad Sci USA 117: 1621–1627. 10.1073/pnas.1914912117.31882447
Miller, CA; Cohen, MD; Costa, M. (1991). Complexing of actin and other nuclear proteins to DNA by cis-diamminedichloroplatinum(II) and chromium compounds. Carcinogenesis 12: 269–276.1995193
Miller, CA, III; Costa, M. (1988). Characterization of DNA-protein complexes induced in intact cells by the carcinogen chromate. Mol Carcinog 1: 125–133. 10.1002/mc.2940010208.3151260
Miller, CA, III; Costa, M. (1989). Immunological detection of DNA-protein complexes induced by chromate. Carcinogenesis 10: 667–672. 10.1093/carcin/10.4.667.2649265
Minder, CE; Beerporizek, V. (1992). Cancer mortality of Swiss men by occupation, 1979–1982. Scand J Work Environ Health 18: 1–27.
Minigaliyeva, IA; Katsnelson, BA; Privalova, LI; Gurvich, VB; Panov, VG; Varaksin, AN; Makeyev, OH; Sutunkova, MP; Loginova, NV; Kireyeva, EP; Grigoryeva, EV; Slyshkina, TV; Ganebnykh, EV; Grebenkina, SV. (2014). Toxicodynamic and toxicokinetic descriptors of combined chromium (VI) and nickel toxicity. Int J Toxicol 33: 498–505. 10.1177/1091581814555915.25355735
Minoia, C; Cavalleri, A. (1988). Chromium in urine, serum and red blood cells in the biological monitoring of workers exposed to different chromium valency states. Sci Total Environ 71: 323–327. 10.1016/0048-9697(88)90204-5.3406705
Minoia, C; Cavalleri, A; D'Andrea, F. (1983). Urinary excretion of total and hexavalent chromium in workers exposed to trivalent chromium and hexavalent chromium. In Braetter, P And P Schramel (Ed) Trace Element Analytical Chemistry in Medicine and Biology, Vol 2 Proceedings of the International Workshop, Neuherberg, West Germany, April 1982 Xvi+1189p Walter De Gruyter: Berlin, West Germany; New York, NY, USA Illus Isbn 3–11-008681–6; 0 (0) 1983 P623–626.
Mirsalis, JC; Hamilton, CM; OĽoughlin, KG; Paustenbach, DJ; Kerger, BD; Patierno, S. (1996). Chromium (VI) at plausible drinking water concentrations is not genotoxic in the in vivo bone marrow micronucleus or liver unscheduled DNA synthesis assays. Environ Mol Mutagen 28: 60–63. 10.1002/(SICI)1098-2280(1996)28:1<60::AID-EM9>3.0.CO;2-I.8698048
Mitchell, AD; Rudd, CJ; Caspary, WJ. (1988). Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at sri international. Environ Mutagen 12: 37–101. 10.1002/em.2860120504.
Mitrov, D; Hadzi-Petrushev, N; Stojkovski, V; Gjorgievska, E; Gagov, H; Mladenov, M. (2014). Influence of chronic chromium exposition on the processes of lipid peroxidation inflammation and platelet activation in rats [Letter]. J Biol Regul Homeost Agents 28: 531–535.25316141
Miyai, T. (1980). Absorption and accumulation of chromium in animals after chromium compound inhalation: 1. Accumulation in rats by long-term inhalation (pp. 193–209). (HEEP/81/07171). Miyai, T.
Miyai, T; Fujii, N; Suzuki, Y. (1980). [Absorption and accumulation of chromium in animals after chromium compound inhalation: 2. comparison of various chromium compounds]. Shikoku Acta Medica 36: 210–223.
Miyasaka, K; Ohta, M; Kanai, S; Yoshida, Y; Sato, N; Nagata, A; Matsui, T; Noda, T; Jimi, A; Takiguchi, S; Takata, Y; Kawanami, T; Funakoshi, A. (2004). Enhanced gastric emptying of a liquid gastric load in mice lacking cholecystokinin-B receptor: A study of CCK-A,B, and AB receptor gene knockout mice. J Gastroenterol 39: 319–323. 10.1007/s00535-003-1297-2.15168241
Moffat, I, vy; Martinova, N; Seidel, C; Thompson, CM. (2018). Hexavalent Chromium in Drinking Water. J Am Water Works Assoc 110: E22–E35. 10.1002/awwa.1044.
Montanaro, F; Ceppi, M; Demers, PA; Puntoni, R; Bonassi, S. (1997). Mortality in a cohort of tannery workers. Occup Environ Med 54: 588–591. 10.1136/oem.54.8.588.9326162
Morgan, RW; Kaplan, SD; Gaffey, WR. (1981). A general mortality study of production workers in the paint and coatings manufacturing industry. A preliminary report. J Occup Med 23: 13–21.7205412
Morse, JL; Luczak, MW; Zhitkovich, A. (2013). Chromium(VI) causes interstrand DNA cross-linking in vitro but shows no hypersensitivity in cross-link repair-deficient human cells. Chem Res Toxicol 26: 1591–1598. 10.1021/tx400293s.24059640
Moulin, JJ. (1995). Assessment of risk of lung cancer among mild steel and stainless steel welders [Letter]. Occup Environ Med 52: 284–285.
Moulin, JJ; Clavel, T; Roy, D; Dananché, B; Marquis, N; Févotte, J; Fontana, JM. (2000). Risk of lung cancer in workers producing stainless steel and metallic alloys. Int Arch Occup Environ Health 73: 171–180. 10.1007/s004200050024.10787132
Moulin, JJ; Portefaix, P; Wild, P; Mur, JM; Smagghe, G; Mantout, B. (1990). Mortality study among workers producing ferroalloys and stainless steel in France. Br J Ind Med 47: 537–543. 10.1136/oem.47.8.537.2393634
Moulin, JJ; Wild, P; Haguenoer, JM; Faucon, D; De Gaudemaris, R; Mur, JM; Mereau, M; Gary, Y; Toamain, JP; Birembaut, Y. (1993a). A mortality study among mild steel and stainless steel welders. Br J Ind Med 50: 234–243. 10.1136/oem.50.3.234.8457490
Moulin, JJ; Wild, P; Mantout, B; Fournier-Betz, M; Mur, JM; Smagghe, G. (1993b). Mortality from lung cancer and cardiovascular diseases among stainless-steel producing workers. Cancer Causes Control 4: 75–81. 10.1007/BF00053147.8386949
Mozafari, P; Rezazadeh Azari, M; Shokoohi, Y; Sayadi, M. (2016). Feasibility of biological effective monitoring of chrome electroplaters to chromium through analysis of serum malondialdehyde. Int J Occup Environ Med 7: 199–206. 10.15171/ijoem.2016.782.27651080
Mudie, DM; Amidon, GL; Amidon, GE. (2010). Physiological parameters for oral delivery and in vitro testing [Review]. Mol Pharm 7: 1388–1405. 10.1021/mp100149j.20822152
Mudie, DM; Murray, K; Hoad, CL; Pritchard, SE; Garnett, MC; Amidon, GL; Gowland, PA; Spiller, RC; Amidon, GE; Marciani, L. (2014). Quantification of gastrointestinal liquid volumes and distribution following a 240 ml dose of water in the fasted state. Mol Pharm 11: 3039–3047. 10.1021/mp500210c.25115349
Muller, CD; Garcia, SC; Brucker, N; Goethel, G; Sauer, E; Lacerda, LM; Oliveira, E; Trombini, TL; Machado, AB; Pressotto, A; Rech, VC; Klauck, CR; da Silva, LB; Gioda, A; Feksa, LR. (2020). Occupational risk assessment of exposure to metals in chrome plating workers. Drug Chem Toxicol 45: 1–8. 10.1080/01480545.2020.1731527.32013615
Murthy, RC; Saxena, DK; Gupta, SK; Chandra, SV. (1991). Ultrastructural observations in testicular tissue of chromium-treated rats. Reprod Toxicol 5: 443–447. 10.1016/0890-6238(91)90008-4.1806154
Muttamara, S; Leong, ST. (2004). Health implication among occupational exposed workers in a chromium alloy factory, Thailand. J Environ Sci 16: 181–186.
Mutti, A; Cavatorta, A; Borghi, L; Canali, M; Giaroli, C; Franchini, I. (1979). Distribution and urinary excretion of chromium. Studies on rats after administration of single and repeated doses of potassium dichromate. Med Lav 70: 171–179.470819
Myers, CR; Antholine, WE; Myers, JM. (2010). The pro-oxidant chromium(VI) inhibits mitochondrial complex I, complex II, and aconitase in the bronchial epithelium: EPR markers for Fe-S proteins. Free Radic Biol Med 49: 1903–1915. 10.1016/j.freeradbiomed.2010.09.020.20883776
Myers, CR; Myers, JM. (1998). Iron stimulates the rate of reduction of hexavalent chromium by human microsomes. Carcinogenesis 19: 1029–1038. 10.1093/carcin/19.6.1029.9667741
Myers, JM; Antholine, WE; Myers, CR. (2008). Hexavalent Chromium Causes the Oxidation of Thioredoxin in Human Bronchial Epithelial Cells. Toxicology 246(2–3): 222–233. 10.1016/j.tox.2008.01.017.18328613
Myers, JM; Antholine, WE; Myers, CR. (2011). The intracellular redox stress caused by hexavalent chromium is selective for proteins that have key roles in cell survival and thiol redox control. Toxicology 281: 37–47. 10.1016/j.tox.2011.01.001.21237240
Myers, JM; Myers, CR. (2009). The effects of hexavalent chromium on thioredoxin reductase and peroxiredoxins in human bronchial epithelial cells. Free Radic Biol Med 47: 1477–1485. 10.1016/j.freeradbiomed.2009.08.015.19703554
Myhr, BC; Caspary, WJ. (1988). Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12: 103–194. 10.1002/em.2860120505.3416838
Nagaya, T. (1986). No increase in sister-chromatid exchange frequency in lymphocytes of chromium platers. Mutat Res 170: 129–132.3713723
Nagaya, T; Ishikawa, N; Hata, H. (1989). Sister chromatid exchange analysis in lymphocytes of workers exposed to hexavalent chromium. Br J Ind Med 46: 48–51.2920143
Nagaya, T; Ishikawa, N; Hata, H; Otobe, T. (1991). Sister-chromatid exchanges in lymphocytes from 12 chromium platers: a 5-year follow-up study. Toxicol Lett 58: 329–335.1957328
Nakamura, SI; Oda, Y; Shimada, T; Oki, I; Sugimoto, K. (1987). SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination of 151 chemicals. Mutat Res Lett 192: 239–246. 10.1016/0165-7992(87)90063-7.
Nakamuro, K; Yoshikawa, K; Sayato, Y; Kurata, H. (1978). Comparative studies of chromosomal aberration and mutagenicity of trivalent and hexavalent chromium. Mutat Res 58: 175–181.745615
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA's ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Navin, AK; Aruldhas, MM; Navaneethabalakrishnan, S; Mani, K; Michael, FM; Srinivasan, N; Banu, SK. (2021). Prenatal exposure to hexavalent chromium disrupts testicular steroidogenic pathway in peripubertal F1 rats. Reprod Toxicol 101: 63–73. 10.1016/j.reprotox.2021.01.014.33675932
Navya, K; Kumar, GP; Anilakumar, KR. (2017). Ameliorating effect of Curculigo orchoides on chromium(VI) induced oxidative stress via, modulation of cytokines, transcription factors and apoptotic genes. J Appl Biomed 15: 299–306. 10.1016/j.jab.2017.03.003.
Ndaw, S; Leso, V; Bousoumah, R; Rémy, A; Bocca, B; Duca, RC; Godderis, L; Hardy, E; Janasik, B; van Nieuwenhuyse, A; Pinhal, H; Poels, K; Porras, SP; Ruggieri, F; Santonen, T; Santos, SR; Scheepers, PTJ; Silva, MJ; Verdonck, J; ... Iavicoli, I. (2022). HBM4EU chromates study -Usefulness of measurement of blood chromium levels in the assessment of occupational Cr(VI) exposure. Environ Res 214: 113758. 10.1016/j.envres.2022.113758.35764127
Neal-Kluever, A; Fisher, J; Grylack, L; Kakiuchi-Kiyota, S; Halpern, W. (2019). Physiology of the Neonatal Gastrointestinal System Relevant to the Disposition of Orally Administered Medications. Drug Metab Dispos 47: 296–313. 10.1124/dmd.118.084418.30567878
Nemec, AA; Barchowsky, A. (2009). Signal transducer and activator of transcription 1 (STAT1) is essential for chromium silencing of gene induction in human airway epithelial cells. Toxicol Sci 110: 212–223. 10.1093/toxsci/kfp084.19403854
Nemec, AA; Zubritsky, LM; Barchowsky, A. (2010). Chromium(VI) stimulates Fyn to initiate innate immune gene induction in human airway epithelial cells. Chem Res Toxicol 23: 396–404. 10.1021/tx900365u.19994902
Newman, MC. (2008). "What exactly are you inferring?" A closer look at hypothesis testing. Environ Toxicol Chem 27: 1013–1019. 10.1897/07-373.1.18419185
Newton, MF; Lilly, LJ. (1986). Tissue-specific clastogenic effects of chromium and selenium salts in vivo. Mutat Res 169: 61–69.3945238
Nijs, M; Kirsch-Volders, M. (1986). Induction of spindle inhibition and abnormal mitotic figures by Cr(II), Cr(III) and Cr(VI) ions. Mutagenesis 1: 247–252. 10.1093/mutage/1.4.247.2457779
Ning, J; Grant, MH. (1999). Chromium (VI)-induced cytotoxicity to osteoblast-derived cells. Toxicol In Vitro 13: 879–887.20654563
Ning, J; Grant, MH. (2000). The role of reduced glutathione and glutathione reductase in the cytotoxicity of chromium (VI) in osteoblasts. Toxicol In Vitro 14: 329–335.10906439
Ning, J; Henderson, C; Grant, MH. (2002). The cytotoxicity of chromium in osteoblasts: Effects on macromolecular synthesis. J Mater Sci Mater Med 13: 47–52. 10.1023/A:1013630401959.15348204
NIOSH (National Institute for Occupational Safety and Health). (2013). Criteria for a recommended standard: Occupational exposure to hexavalent chromium. (NIOSH Publication Number 2013–128). Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/docs/2013-128/pdfs/2013_128.pdf?id=10.26616/NIOSHPUB2013128.
Nishio, A; Uyeki, EM. (1985). Inhibition of DNA synthesis by chromium compounds. J Toxicol Environ Health 15: 237–244. 10.1080/15287398509530650.3892022
Nishioka, H. (1975). Mutagenic activities of metal compounds in bacteria. Mutat Res 31: 185–189. 10.1016/0165-1161(75)90088-6.805366
NJ DEP (New Jersey Department of Environmental Protection). (2008). Health Consultation: Analysis of Lung Cancer Incidence near Chromium-Contaminated Sites in New Jersey (a/k/a Hudson County Chromium Sites) Jersey City, Hudson County, New Jersey. 56.
NJ DEP (New Jersey Department of Environmental Protection). (2009). Derivation of ingestion-based soil remediation criterion for Cr+6 based on the NTP chronic bioassay data for Sodium Dichromate Dihydrate. http://www.state.nj.us/dep/dsr/chromium/soil-cleanupderivation.pdf.
Nomiyama, H; Yotoriyama, M; Nomiyama, K. (1980). Normal chromium levels in urine and blood of Japanese subjects determined by direct flameless atomic absorption spectrophotometry, and valency of chromium in urine after exposure to hexavalent chromium. Am Ind Hyg Assoc J 41: 98–102. 10.1080/15298668091424438.15508483
Norseth, T; Alexander, J; Aaseth, J; Langard, S. (1982). Biliary excretion of chromium in the rat: a role of glutathione. Basic Clin Pharmacol Toxicol 51: 450–455.
NTP (National Toxicology Program). (1996). Final report on the reproductive toxicity of potassium dichromate (hexavalent) (CAS No. 7778–50-9) administered in diet to BALB/c mice [NTP]. Research Triangle Park: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB97125363.xhtml.
NTP (National Toxicology Program). (1997). Final report on the reproductive toxicity of potassium dichromate (CAS No. 7778–50-9) administered in diet to BALB/c mice [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB97144919.xhtml.
NTP. (2005). Immunotoxicity of hexavalent chromium in female B6C3F1 mice. Protocol: RF-HCR-28–1 M-DW. RTP: NIEHS.
NTP. (2006a). Immunotoxicity of hexavalent chromium in female Fischer 344 rats. Protocol: RF-HCR-28–2R-DW. RTP: NIEHS.
NTP. (2006b). Immunotoxicity of hexavalent chromium in female Sprague Dawley rats. Protocol: RF-HCR-28–1R-DW. RTP: NIEHS.
NTP (National Toxicology Program). (2007a). NTP historical controls report. All routes and vehicles: Mice [NTP]. Research Triangle Park, NC.
NTP (National Toxicology Program). (2007b). NTP historical controls report. All routes and vehicles: Rats [NTP]. Research Triangle Park, NC.
NTP (National Toxicology Program). (2007c). NTP historical controls report. By route and vehicle: Mice [NTP]. Research Triangle Park, NC.
NTP (National Toxicology Program). (2007d). NTP historical controls report. By route and vehicle: Rats [NTP]. Research Triangle Park, NC.
NTP (National Toxicology Program). (2007e). NTP pathology tables, survival and growth curves for TR-546. Research Triangle Park, NC. Retrieved from https://ntp.niehs.nih.gov/results/path/tablelistings/longterm/tr500599/tr546/index.html
NTP (National Toxicology Program). (2007f). NTP technical report on the toxicity studies of sodium dichromate dihydrate (CAS No. 7789–12-0) administered in drinking water to male and female F344/N rats and B6C3F1 mice and male BALB/c and am3-C57BL/6 mice. (Toxicity Report Series Number 72; NIH Publication No. 07–5964). Research Triangle Park, NC. https://ntp.niehs.nih.gov/publications/reports/tox/000s/tox072.
NTP (National Toxicology Program). (2008). Toxicology and carcinogenesis studies of sodium dichromate dihydrate (Cas No. 7789–12-0) in F344/N rats and B6C3F1 mice (drinking water studies) (pp. 1–192). (NTP TR 546; NIH Publication No. 08–5887).
NTP (National Toxicology Program). (2011). Report on carcinogens. Twelfth Edition, 2011 (12th ed., pp. 507). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2011111646.xhtml.
Nudler, SI; Quinteros, FA; Miler, EA; Cabilla, JP; Ronchetti, SA; Duvilanski, BH. (2009). Chromium VI administration induces oxidative stress in hypothalamus and anterior pituitary gland from male rats. Toxicol Lett 185: 187–192. 10.1016/j.toxlet.2009.01.003.19167472
O'Brien, P; Wang, GF; Wyatt, PB. (1992). Studies of the kinetics of the reduction of chromate by glutathione and related thiols. Polyhedron 11: 3211–3216. 10.1016/s0277-5387(00)83664-5.
O'Brien, TJ; Ding, H; Suh, M; Thompson, CM; Parsons, BL; Harris, MA; Winkelman, WA; Wolf, JC; Hixon, JG; Schwartz, AM; Myers, MB; Haws, LC; Proctor, DM. (2013). Assessment of K-Ras mutant frequency and micronucleus incidence in the mouse duodenum following 90-days of exposure to Cr(VI) in drinking water. Mutat Res 754: 15–21. 10.1016/j.mrgentox.2013.03.008.23583686
O'Flaherty, EJ; Radike, MJ. (1991). Pharmacokinetic modeling of trivalent and hexavalent chromium based on ingestion and inhalation of soluble chromium compounds. (AL-TR-1991–0162). Wright-Patterson AFB, Ohio: Armstrong Laboratory. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=ADA256238.
O'Hara, KA; Klei, LR; Barchowsky, A. (2003). Selective activation of Src family kinases and JNK by low levels of chromium(VI). Toxicol Appl Pharmacol 190: 214–223. 10.1016/S0041-008X(03)00188-1.12902192
O'Hara, KA; Vaghjiani, RJ; Nemec, AA; Klei, LR; Barchowsky, A. (2007). Cr(VI)-stimulated STAT3 tyrosine phosphorylation and nuclear translocation in human airway epithelial cells requires Lck. Biochem J 402: 261–269. 10.1042/BJ20061427.17078813
O’Hara; Vaghjiani; Klei; Barchowsky. (2005). Chromium(VI) Activates Stat3 In Bronchial Epithelial Cells [Abstract]. Toxicol Sci 84: 232.15673846
O’Hara, KA; Klei, LR; Vaghjiani, RJ; Barchowsky, A. (2004). Selective signaling pathways for chromium(VI) induced patterns of transcription factor binding in exposed airway epithelial cells [Abstract]. Toxicologist 78: 239.
Oberly, TJ; Piper, CE; McDonald, DS. (1982). Mutagenicity of metal salts in the L5178Y mouse lymphoma assay. J Toxicol Environ Health 9: 367–376. 10.1080/15287398209530170.7097791
OECD (Organisation for Economic Co-operation and Development). (2016). Test no. 474: Mammalian erythrocyte micronucleus test [Standard]. In OECD guidelines for the testing of chemicals Section 4, health effects. Paris, France: OECD Publishing. 10.1787/9789264264762-en.
Ogawa, E; Tsuzuki, H; Yamazaki, Y. (1976). Experimental study on absorption distribution and excretion of trivalent and hexavalent chromium compounds [Abstract]. Jpn J Pharmacol 26: 92.
Ohno, H; Hanaoka, F; Yamada, M. (1982). Inducibility of sister-chromatid exchanges by heavy-metal ions. Mutat Res 104: 141–145. 10.1016/0165-7992(82)90135-x.7078567
Ohta, H; Soewarno, T; Yoshikawa, H. (1980). Distribution of chromium and induction of metallothionein-like protein in rat livers injected with trivalent and hexavalent chromium. Acta Sch Med Univ Gifu 28: 205–210.
Ohta, Y; Inui, M. (1992). Concentration of Accumulated Substances in the Human Lung with Special Regard to the Toxic Effects of Hexavalent Chromium in a Factory Worker.
Olivier, P; Marzin, D. (1987). Study of the genotoxic potential of 48 inorganic derivatives with the SOS chromotest. Mutat Res Genet Toxicol 189: 263–269. 10.1016/0165-1218(87)90057-7.
Olsen, JH; Moller, H; Jensen, OM. (1988). Risks for respiratory and gastric-cancer in woodworking occupations in Denmark. J Cancer Res Clin Oncol 114: 420–424. 10.1007/BF02128189.3410880
Olsson, AC; Vermeulen, R; Schüz, J; Kromhout, H; Pesch, B; Peters, S; Behrens, T; Portengen, L; Mirabelli, D; Gustavsson, P; Kendzia, B; Almansa, J; Luzon, V; Vlaanderen, J; Stücker, I; Guida, F; Consonni, D; Caporaso, N; Landi, MT; Field, J; Brüske, I; Wichmann, HE; Siemiatycki, J; Parent, ME; Richiardi, L; Merletti, F; Jöckel, KH; Ahrens, W; Pohlabeln, H; Plato, N; Tardón, A; Zaridze, D; Mclaughlin, J; Demers, P; Szeszenia-Dabrowska, N; Lissowska, J; Rudnai, P; Fabianova, E; Stanescu Dumitru, R; Bencko, V; Foretova, L; Janout, V; Boffetta, P; Bueno-De-Mesquita, B; Forastiere, F; Brüning, T; Straif, K. (2017). Exposure-response analyses of asbestos and lung cancer subtypes in a pooled analysis of case-control studies. Epidemiology 28: 288–299. 10.1097/EDE.0000000000000604.28141674
Oregon DEQ (Oregon Department of Environmental Quality). (2016a). Bullseye Glass area-wide soil sampling report. Portland, OR.
Oregon DEQ (Oregon Department of Environmental Quality). (2016b). Portland Metals air monitoring data. Portland, OR.
Oregon DEQ (Oregon Department of Environmental Quality). (2016c). Uroboros Glass area-wide soil sampling report. Portland, OR. http://www.oregon.gov/deq/FilterDocs/soilsamplingUro.pdf.
Ormos, G; Mányai, S. (1974). Chromate uptake by human red blood cells: comparison of permeability for different divalent anions. Acta Biochim Biophys Acad Sci Hung 9: 197–207.4422059
Ormos, G; Mányai, S. (1977). Chemical modification of erythrocytes. Effect on the velocity of chromate uptake. Acta Biochim Biophys Acad Sci Hung 12: 343–352.207066
Ortega, R; Fayard, B; Salome, M; Deves, G; Susini, J. (2005). Chromium oxidation state imaging in mammalian cells exposed in vitro to soluble or particulate chromate compounds. Chem Res Toxicol 18: 1512–1519. 10.1021/tx049735y.16533014
OSHA (Occupational Safety & Health Administration). (2006a). Asbestos-automotive brake and clutch repair work. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. https://www.osha.gov/dts/shib/shib072606.html.
OSHA (Occupational Safety & Health Administration). (2006b). Occupational exposure to hexavalent chromium. Final rule. Fed Reg 71: 10099–10385.
Osinski, MA; Seifert, TR; Cox, BF; Gintant, GA. (2002). An improved method of evaluation of drug-evoked changes in gastric emptying in mice. J Pharmacol Toxicol Methods 47: 115–120. 10.1016/S1056-8719(02)00217-4.12459151
Ottenwaelder, H; Wiegand, HJ; Bolt, HM. (1988). Uptake of 51Cr(VI) by human erythrocytes: Evidence for a carrier-mediated transport mechanism. Sci Total Environ 71: 561–566. 10.1016/0048-9697(88)90237-9.3406724
Ottenwälder, H; Wiegand, HJ; Bolt, HM. (1987). Membrane permeability and intracellular disposition of 51Cr(VI) in human red blood cells. Toxicol Environ Chem 14: 219–226. 10.1080/02772248709357205.
Ovesen, JL; Fan, Y; Zhang, X; Chen, J; Medvedovic, M; Xia, Y; Puga, A. (2014). Formaldehyde-Assisted Isolation of Regulatory Elements (FAIRE) Analysis Uncovers Broad Changes in Chromatin Structure Resulting from Hexavalent Chromium Exposure. PLoS ONE 9: e97849. 10.1371/journal.pone.0097849.24837440
Palmen, NGM; Geraets, L; ter Burg, W; Bos, PMJ; Hessel, EVS; Staal, YCM; Ezendam, J; Piersma, AH. (2018). [Health effects and risk assessment of chromium-6 exposure at the POMS sites of the Ministry of Defence]. (RIVM Report 2018–0053). Bilthoven, Netherlands: Rijksinstituut voor Volksgezondheid en Milieu RIVM. 10.21945/RIVM-2018-0053.
Pan, CH; Jeng, HA; Lai, CH. (2017). Biomarkers of oxidative stress in electroplating workers exposed to hexavalent chromium. J Expo Sci Environ Epidemiol 28: 76–83. 10.1038/jes.2016.85.28120834
Parent, ME; Siemiatycki, J; Fritschi, L. (1998). Occupational exposures and gastric cancer. Epidemiology 9: 48–55. 10.1097/00001648-199801000-00011.9430268
Park, R; Krebs, J; Mirer, F. (1994). Mortality at an automotive stamping and assembly complex. Am J Ind Med 26: 449–463.7810544
Park, RM; Ahn, YS; Stayner, LT; Kang, SK; Jang, JK. (2005). Mortality of iron and steel workers in Korea. Am J Ind Med 48: 194–204. 10.1002/ajim.20197.16094610
Park, RM; Bena, JF; Stayner, LT; Smith, RJ; Gibb, HJ; Lees, PS. (2004). Hexavalent chromium and lung cancer in the chromate industry: a quantitative risk assessment. Risk Anal 24: 1099–1108. 10.1111/j.0272-4332.2004.00512.x.15563281
Park, RM; Stayner, LT. (2006). A search for thresholds and other nonlinearities in the relationship between hexavalent chromium and lung cancer. Risk Anal 26: 79–88. 10.1111/j.1539-6924.2006.00709.x.16492182
Park, S; Li, C; Zhao, H; Darzynkiewicz, Z; Xu, D. (2016). Gene 33/Mig6 inhibits hexavalent chromium-induced DNA damage and cell transformation in human lung epithelial cells. Onct 7: 8916–8930. 10.18632/oncotarget.6866.
Park, S; Zhang, X; Li, C; Yin, C; Li, J; Fallon, JT; Huang, W; Xu, D. (2017). Single-cell RNA sequencing reveals an altered gene expression pattern as a result of CRISPR/cas9-mediated deletion of Gene 33/Mig6 and chronic exposure to hexavalent chromium in human lung epithelial cells. Toxicol Appl Pharmacol 330: 30–39. 10.1016/j.taap.2017.07.003.28688920
Park, YH; Kim, D; Dai, J; Zhang, Z. (2015). Human bronchial epithelial BEAS-2B cells, an appropriate in vitro model to study heavy metals induced carcinogenesis. Toxicol Appl Pharmacol 287: 240–245. 10.1016/j.taap.2015.06.008.26091798
Parrott, N; Lukacova, V; Fraczkiewicz, G; Bolger, MB. (2009). Predicting pharmacokinetics of drugs using physiologically based modeling--application to food effects [Review]. AAPS J 11: 45–53. 10.1208/s12248-008-9079-7.19184451
Pascal, LE; Tessier, DM. (2004). Cytotoxicity of chromium and manganese to lung epithelial cells in vitro. Toxicol Lett 147: 143–151. 10.1016/j.toxlet.2003.11.004.14757318
Paschin, YV; Kozachenko, VI; Sal'nikova, LE. (1983). Differential mutagenic response at the HGPRT locus in V79 and CHO Chinese hamster cells after treatment with chromate. Mutat Res 122: 361–365.6656819
Paschin, YV; Zacepilova, TA; Kozachenko, VI. (1982). Induction of dominant lethal mutations in male mice by potassium dichromate. Mutat Res 103: 345–347.7087995
Pastides, H; Austin, R; Lemeshow, S; Klar, J; Mundt, KA. (1994). A retrospective-cohort study of occupational exposure to hexavalent chromium. Am J Ind Med 25: 663–675. 10.1002/ajim.4700250506.8030637
Patlolla, AK; Barnes, C; Hackett, D; Tchounwou, PB. (2009a). Potassium dichromate induced cytotoxicity, genotoxicity and oxidative stress in human liver carcinoma (HepG2) cells. Int J Environ Res Public Health 6: 643–653. 10.3390/ijerph6020643.19440407
Patlolla, AK; Barnes, C; Yedjou, C; Velma, VR; Tchounwou, PB. (2009b). Oxidative Stress, DNA Damage, and Antioxidant Enzyme Activity Induced by Hexavalent Chromium in Sprague-Dawley Rats. Environ Toxicol 24: 66–73. 10.1002/tox.20395.18508361
Paustenbach, DJ; Hays, SM; Brien, BA; Dodge, DG; Kerger, BD. (1996). Observation of steady state in blood and urine following human ingestion of hexavalent chromium in drinking water. J Toxicol Environ Health 49: 453–461. 10.1080/009841096160682.8968407
Pedersen, DH; Sieber, WK. (1988). National occupational exposure survey Volume III: analysis of management interview responses. Pedersen, DH; Sieber, WK.
Percy, C; Stanek, E, III; Gloeckler, L. (1981). Accuracy of cancer death certificates and its effect on cancer mortality statistics. Am J Public Health 71: 242–250. 10.2105/AJPH.71.3.242.7468855
Percy, CL; Miller, BA; Gloeckler Ries, LA. (1990). Effect of changes in cancer classification and the accuracy of cancer death certificates on trends in cancer mortality. Ann N Y Acad Sci 609: 87–99. 10.1111/j.1749-6632.1990.tb32059.x.2264660
Pereira, M; Pereira, M; Sousa, JP. (1999). Individual study of chromium in the stainless steel implants degradation: an experimental study in mice. Biometals 12: 275–280.10581692
Perrault, G; Dufresne, A; Strati, G; Mcneil, M; Michaud, D; Baril, M; Bégin, R; Labbé, J; Larivière, P; Eeckhaoudt, S. (1995). Physico-chemical fate of chromium compounds in the sheep lung model. J Toxicol Environ Health 44: 247–262. 10.1080/15287399509531958.7853424
Pesch, B; Kendzia, B; Pohlabeln, H; Ahrens, W; Wichmann, HE; Siemiatycki, J; Taeger, D; Zschiesche, W; Behrens, T; Jöckel, KH; Brüning, T. (2019). Exposure to Welding Fumes, Hexavalent Chromium, or Nickel and Risk of Lung Cancer. Am J Epidemiol 188: 1984–1993. 10.1093/aje/kwz187.31504103
Pesch, B; Lehnert, M; Weiss, T; Kendzia, B; Menne, E; Lotz, A; Heinze, E; Behrens, T; Gabriel, S; Schneider, W; Brüning, T. (2018). Exposure to hexavalent chromium in welders: Results of the WELDOX II field study. 62: 351–361. 10.1093/annweh/wxy004.
Peters, S; Vermeulen, R; Portengen, L; Olsson, A; Kendzia, B; Vincent, R; Savary, B; Lavoué, J; Cavallo, D; Cattaneo, A; Mirabelli, D; Plato, N; Fevotte, J; Pesch, B; Brüning, T; Straif, K; Kromhout, H. (2016). SYN-JEM: A Quantitative Job-Exposure Matrix for Five Lung Carcinogens. Ann Occup Hyg 60: 795–811. 10.1093/annhyg/mew034.27286764
Peterson-Roth, E; Reynolds, M; Quievryn, G; Zhitkovich, A. (2005). Mismatch repair proteins are activators of toxic responses to chromium-DNA damage. Mol Cell Biol 25: 3596–3607. 10.1128/MCB.25.9.3596-3607.2005.15831465
Petrilli, FL; De Flora, S. (1977). Toxicity and mutagenicity of hexavalent chromium on Salmonella typhimurium. Appl Environ Microbiol 33: 805–809.326184
Petrilli, FL; De Flora, S. (1982). Interpretations on chromium mutagenicity and carcinogenicity. In M Sorsa; H Vainio (Eds.), Mutagens in our environment: Proceedings of the twelfth annual meeting of the European Environmental Mutagen Society (pp. 453–464). New York, NY: A. R. Liss.
Petrilli, FL; Rossi, GA; Camoirano, A; Romano, M; Serra, D; Bennicelli, C; De Flora, A; De Flora, S. (1986). Metabolic reduction of chromium by alveolar macrophages and its relationships to cigarette smoke. J Clin Invest 77: 1917–1924. 10.1172/JCI112520.2423559
Petruzzelli, S; De Flora, S; Bagnasco, M; Hietanen, E; Camus, AM; Saracci, R; Izzotti, A; Bartsch, H; Giuntini, C. (1989). Carcinogen metabolism studies in human bronchial and lung parenchymal tissues. Am Rev Respir Dis 140: 417–422. 10.1164/ajrccm/140.2.417.2504089
PHS (U.S. Public Health Service). (1953). Health of workers in chromate producing industry. (No. 192). Washington, DC.
Pierre, F; Fo, D; Fo, B. (2008). Biomonitoring of two types of chromium exposure in an electroplating shop. Int Arch Occup Environ Health 81: 321–329. 10.1007/s00420-007-0216-x.17605030
Pippard, EC; Acheson, ED; Winter, PD. (1985). Mortality of tanners. Br J Ind Med 42: 285–287. 10.1136/oem.42.4.285.3978050
Polednak, AP. (1981). Mortality among welders, including a group exposed to nickel oxides. Arch Environ Occup Health 36: 235–242.
Pool-Zobel, BL; Lotzmann, N; Knoll, M; Kuchenmeister, F; Lambertz, R; Leucht, U; Schröder, HG; Schmezer, P. (1994). Detection of genotoxic effects in human gastric and nasal mucosa cells isolated from biopsy samples. Environ Mol Mutagen 24: 23–45. 10.1002/em.2850240105.7519553
Popp, W; Vahrenholz, C; Schmieding, W; Krewet, E; Norpoth, K. (1991). Investigations of the frequency of DNA strand breakage and cross-linking and of sister chromatid exchange in the lymphocytes of electric welders exposed to chromium- and nickel-containing fumes. Int Arch Occup Environ Health 63: 115–120. 10.1007/BF00379074.1889880
Popper, HH; Grygar, E; Ingolic, E; Wawschinek, O. (1993). Cytotoxicity of chromium-III and chromium-VI compounds. I. In vitro studies using different cell culture systems. Inhal Toxicol 5: 345–369. 10.3109/08958379308998392.
Poulakos, L; Kent, TH. (1973). Gastric emptying and small intestinal propulsion in fed and fasted rats. Gastroenterology 64: 962–967. 10.1016/S0016-5085(73)80008-3.4700423
Pournourmohammadi, S; Khazaelp, P; Eslamizad, S; Tajvar, A; Mohammadirad, A; Abdollahi, M. (2008). Study on the oxidative stress status among cement plant workers. Hum Exp Toxicol 27: 463–469. 10.1177/0960327108094956.18784198
Pratt, PF; Myers, CR. (1993). Enzymatic reduction of chromium(VI) by human hepatic microsomes. Carcinogenesis 14: 2051–2057. 10.1093/carcin/14.10.2051.8222053
Pritchard, DE; Ceryak, S; Ha, L; Fornsaglio, JL; Hartman, SK; O'Brien, TJ; Patierno, S. R. (2001). Mechanism of apoptosis and determination of cellular fate in chromium(VI)-exposed populations of telomerase-immortalized human fibroblasts. Cell Growth Differ 12: 487–496.11682460
Pritchard, DE; Ceryak, S; Ramsey, KE; O'Brien, TJ; Ha, LN; Fornsaglio, JL; Stephan, DA; Patierno, P, SR. (2005). Resistance to apoptosis, increased growth potential, and altered gene expression in cells that survived genotoxic hexavalent chromium Cr(VI) exposure. Mol Cell Biochem 279: 169–181. 10.1007/s11010-005-8292-2.16283527
Pritchard, KA; Ackerman, A; Kalyanaraman, B. (2000). Chromium (VI) increases endothelial cell expression of ICAM-1 and decreases nitric oxide activity. J Environ Pathol Toxicol Oncol 19: 251–260.10983891
Proctor, DM; Bhat, V; Suh, M; Reichert, H; Jiang, X; Thompson, CM. (2021). Inhalation cancer risk assessment for environmental exposure to hexavalent chromium: Comparison of margin-of-exposure and linear extrapolation approaches [Review]. Regul Toxicol Pharmacol 124: 104969. 10.1016/j.yrtph.2021.104969.34089813
Proctor, DM; Suh, M; Aylward, LL; Kirman, CR; Harris, MA; Thompson, CM; Gürleyük, H; Gerads, R; Haws, LC; Hays, SM. (2012). Hexavalent chromium reduction kinetics in rodent stomach contents. Chemosphere 89: 487–493. 10.1016/j.chemosphere.2012.04.065.22682893
Proctor, DM; Suh, M; Mittal, L, iz; Hirsch, S; Salgado, RV; Bartlett, C; Van Landingham, C; Rohr, A; Crump, K. (2016). Inhalation cancer risk assessment of hexavalent chromium based on updated mortality for Painesville chromate production workers. J Expo Sci Environ Epidemiol 26: 224–231. 10.1038/jes.2015.77.26669850
Pukkala, E; Martinsen, J; Lynge, E; Gunnarsdottir, H; Sparén, P; Tryggvadottir, L; Weiderpass, E; Kjaerheim, K. (2009). Occupation and cancer - follow-up of 15 million people in five Nordic countries. Acta Oncol 48: 646–790. 10.1080/02841860902913546.19925375
Purdon, RA; Bass, P. (1973). Gastric and intestinal transit in rats measured by a radioactive test meal. Gastroenterology 64: 968–976. 10.1016/S0016-5085(73)80009-5.4144750
Qayyum, S; Ara, A; Usmani, JA. (2012). Effect of nickel and chromium exposure on buccal cells of electroplaters. Toxicol Ind Health 28: 74–82. 10.1177/0748233711407237.21636684
Qian, Q, in; Li, P; Wang, T; Zhang, J, i; Yu, S; Chen, T; Yan, L, ei; Song, Y; Liu, X; Gu, Y; Wang, Y, un; Jia, G. (2013). Alteration of Th1/Th2/Th17 cytokine profile and humoral immune responses associated with chromate exposure. Occup Environ Med 70: 697–702. 10.1136/oemed-2013-101421.23811143
Qin, Q; Xie, H; Wise, SS; Browning, CL; Thompson, KN; Holmes, AL; Wise, JP. (2014). Homologous recombination repair signaling in chemical carcinogenesis: prolonged particulate hexavalent chromium exposure suppresses the rad51 response in human lung cells. Toxicol Sci 142: 117–125. 10.1093/toxsci/kfu175.25173789
Qu, Q; Li, X; An, F; Jia, G; Liu, L; Watanabe-Meserve, H; Koenig, K; Cohen, B; Costa, M; Roy, N; Zhong, M; Chen, LC; Liu, S; Yan, L. (2008). Cr(VI) exposure and biomarkers: Cr in erythrocytes in relation to exposure and polymorphisms of genes encoding anion transport proteins. Biomarkers 13: 467–477. 10.1080/13547500802099574.18979639
Qualls-Creekmore, E; Tong, M; Holmes, GM. (2010). Gastric emptying of enterally administered liquid meal in conscious rats and during sustained anaesthesia. Neurogastroenterol Motil 22: 181–185. 10.1111/j.1365-2982.2009.01393.x.19735361
Quievryn, G; Goulart, M; Messer, J; Zhitkovich, A. (2001). Reduction of Cr (VI) by cysteine: Significance in human lymphocytes and formation of DNA damage in reactions with variable reduction rates. Mol Cell Biochem 222: 107–118. 10.1023/A:1017923609175.11678591
Quievryn, G; Messer, J; Zhitkovich, A. (2002). Carcinogenic chromium(VI) induces cross-linking of vitamin C to DNA in vitro and in human lung A549 cells. Biochemistry 41: 3156–3167. 10.1021/bi011942z.11863455
Quievryn, G; Messer, J; Zhitkovich, A. (2006). Lower mutagenicity but higher stability of Cr-DNA adducts formed during gradual chromate activation with ascorbate. Carcinogenesis 27: 2316–2321. 10.1093/carcin/bgl076.16714765
Quievryn, G; Peterson, E; Messer, J; Zhitkovich, A. (2003). Genotoxicity and mutagenicity of chromium(VI)/ascorbate-generated DNA adducts in human and bacterial cells. Biochemistry 42: 1062–1070. 10.1021/bi0271547.12549927
Quinteros, FA; Machiavelli, LI; Miler, EA; Cabilla, JP; Duvilanski, BH. (2008). Mechanisms of chromium (VI)-induced apoptosis in anterior pituitary cells. Toxicology 249: 109–115. 10.1016/j.tox.2008.04.012.18547707
Quinteros, FA; Poliandri, AH; Machiavelli, LI; Cabilla, JP; Duvilanski, BH. (2007). In vivo and in vitro effects of chromium VI on anterior pituitary hormone release and cell viability. Toxicol Appl Pharmacol 218: 79–87. 10.1016/j.taap.2006.10.017.17141818
Qureshi, IZ; Mahmood, T. (2010). Prospective role of ascorbic acid (vitamin C) in attenuating hexavalent chromium-induced functional and cellular damage in rat thyroid. Toxicol Ind Health 26: 349–359. 10.1177/0748233710371109.20504825
Rafnsson, V; Gunnarsdottir, H; Kiilunen, M. (1997). Risk of lung cancer among masons in Iceland. Occup Environ Med 54: 184–188.9155779
Rafnsson, V; Jóhannesdóttir, SG. (1986). Mortality among masons in Iceland. Br J Ind Med 43: 522–525.3637113
Rager, JE; Ring, CL; Fry, RC; Suh, M; Proctor, DM; Haws, LC; Harris, MA; Thompson, CM. (2017). High-throughput screening data interpretation in the context of in vivo transcriptomic responses to oral Cr(VI) exposure. Toxicol Sci 158: 199–212. 10.1093/toxsci/kfx085.28472532
Ramanakumar, AV; Nadon, L; Siemiatycki, J. (2008). Exposures in painting related occupations and risk of selected cancers: Results from a case-control study in Montreal. Am J Ind Med 51: 419–427. 10.1002/ajim.20564.18324661
Rao, MV; Chawla, SL; Sharma, SR. (2009). Protective role of vitamin E on nickel and/or chromium induced oxidative stress in the mouse ovary. Food Chem Toxicol 47: 1368–1371. 10.1016/j.fct.2009.03.018.19306907
Rao, MV; Chinoy, NJ; Mitali, R. (1999). Genotoxic effects of potassium dichromate in human blood cultures. Med Sci Res 27: 839–841.
Rasool, M; Zaigham, K; Malik, A; Naseer, MI; Umm-E-Habiba, MI; Manan, A; Qazi, MH; Asif, M. (2014). Potential reproductive health effects and oxidative stress associated with exposure to potassium dichromate (K2Cr2O7) and magnesium sulphate (MgSO4) in male mice. Pakistan Journal of Medical Sciences online 30: 819–823.
Ray, RR; Sarkar, NK. (2012). Light and scanning electron microscopic studies on chromium-induced anemia in a murine model. Bull Environ Contam Toxicol 88: 10–14. 10.1007/s00128-011-0469-7.22080295
Reutter, K; Jaeger, D; Degwert, J; Hoppe, U. (1997). In vitro model for contact sensitization: II. Induction of IL-1beta mRNA in human blood-derived dendritic cells by contact sensitizers. Toxicol In Vitro 11: 619–626. 10.1016/S0887-2333(97)00048-9.20654360
Reynolds, M; Armknecht, S; Johnston, T; Zhitkovich, A. (2012). Undetectable role of oxidative DNA damage in cell cycle, cytotoxic and clastogenic effects of Cr(VI) in human lung cells with restored ascorbate levels. Mutagenesis 27: 437–443. 10.1093/mutage/ger095.22241526
Reynolds, M; Peterson, E; Quievryn, G; Zhitkovich, A. (2004). Human nucleotide excision repair efficiently removes chromium-DNA phosphate adducts and protects cells against chromate toxicity. J Biol Chem 279: 30419–30424. 10.1074/jbc.M402486200.15087443
Reynolds, M; Stoddard, L; Bespalov, I; Zhitkovich, A. (2007). Ascorbate acts as a highly potent inducer of chromate mutagenesis and clastogenesis: linkage to DNA breaks in G2 phase by mismatch repair. Nucleic Acids Res 35: 465–476. 10.1093/nar/gkl1069.17169990
Reynolds, M; Zhitkovich, A. (2007). Cellular vitamin C increases chromate toxicity via a death program requiring mismatch repair but not p53. Carcinogenesis 28: 1613–1620. 10.1093/carcin/bgm031.17301063
Reynolds, MF; Peterson-Roth, EC; Bespalov, IA; Johnston, T; Gurel, VM; Menard, HL; Zhitkovich, A. (2009). Rapid DNA double-strand breaks resulting from processing of Cr-DNA cross-links by both MutS dimers. Cancer Res 69: 1071–1079. 10.1158/0008-5472.CAN-08-2306.19141647
Richelmi, P; Baldi, C; Minoia, C. (1984). Blood levels of hexavalent chromium in rats. "In vitro" and "In vivo" experiments. Int J Environ Anal Chem 17: 181–186. 10.1080/03067318408076971.6746187
Richiardi, L; Corbin, M; Marron, M; Ahrens, W; Pohlabeln, H; Lagiou, P; Minaki, P; Agudo, A; Castellsague, X; Slamova, A; Schejbalova, M; Kjaerheim, K; Barzan, L; Talamini, R; Macfarlane, GJ; Macfarlane, TV; Canova, C; Simonato, L; Conway, DI; Mckinney, PA; Sneddon, L; Thomson, P; Znaor, A; Healy, CM; Mccartan, BE; Benhamou, S; Bouchardy, C; Hashibe, M, ia; Brennan, P; Merletti, F. (2012). Occupation and risk of upper aerodigestive tract cancer: The ARCAGE study. Int J Cancer 130: 2397–2406. 10.1002/ijc.26237.21671472
RIVM (National Institute for Public Health and the Environment (Netherlands)). (2001). Reevaluation of human-toxicological maximum permissible risk levels. (RIVM report 711701025). Bilthoven, Netherlands: National Institute for Public Health and the Environment (RIVM). https://www.rivm.nl/bibliotheek/rapporten/711701025.pdf.
Rizzi, M; Cravello, B; Renò, F. (2014). Textile industry manufacturing by-products induce human melanoma cell proliferation via ERK1/2 activation. Cell Prolif 47: 578–586. 10.1111/cpr.12132.25224575
Robinson, C; Stern, F; Halperin, W; Venable, H; Petersen, M; Frazier, T; Burnett, C; Lalich, N; Salg, J; Sestito, J. (1995). Assessment of mortality in the construction industry in the United States, 1984–1986. Am J Ind Med 28: 49–70.7573075
Robinson, CF; Petersen, M; Sieber, WK; Palu, S; Halperin, WE. (1996). Mortality of Carpenters' Union members employed in the U.S. construction or wood products industries, 1987–1990. Am J Ind Med 30: 674–694. 10.1002/(SICI)1097-0274(199612)30:6&lt;674::AID-AJIM4&gt;3.0.CO;2-R.8914714
Roda, A; Mezzanotte, L; Aldini, R; Michelini, E; Cevenini, L. (2010). A new gastric-emptying mouse model based on in vivo non-invasive bioluminescence imaging. Neurogastroenterol Motil 22: 1117–e1288. 10.1111/j.1365-2982.2010.01535.x.20546505
Rodrigues, CFD; Urbano, AM; Matoso, E; Carreira, I; Almeida, A; Santos, P; Botelho, F; Carvalho, L; Alves, M; Monteiro, C; Costa, AN; Moreno, V; Alpoim, MC. (2009). Human bronchial epithelial cells malignantly transformed by hexavalent chromium exhibit an aneuploid phenotype but no microsatellite instability. Mutat Res Fundam Mol Mech Mutagen 670: 42–52. 10.1016/j.mrfmmm.2009.07.004.
Rosenman, KD; Stanbury, M. (1996). Risk of lung cancer among former chromium smelter workers. Am J Ind Med 29: 491–500. 10.1002/(SICI)1097-0274(199605)29:5<491::AID-AJIM7>3.0.CO;2-P.8732922
Rossi, SC; Gorman, N; Wetterhahn, KE. (1988). Mitochondrial reduction of the carcinogen chromate: formation of chromium (V). Chem Res Toxicol 1: 101–107. 10.1021/tx00002a003.2979716
Rossi, SC; Wetterhahn, KE. (1989). Chromium(V) is produced upon reduction of chromate by mitochondrial electron transport chain complexes. Carcinogenesis 10: 913–920. 10.1093/carcin/10.5.913.2539917
Rothman, K. (2010). Curbing type I and type II errors. Eur J Epidemiol 25: 223–224. 10.1007/s10654-010-9437-5.20232112
Royle, H. (1975a). Toxicity of chromic acid in the chromium plating industry (1). Environ Res 10: 39–53. 10.1016/0013-9351(75)90072-9.1175579
Royle, H. (1975b). Toxicity of chromic acid in the chromium plating industry(2). Environ Res 10: 141–163. 10.1016/0013-9351(75)90079-1.1175577
Rudnykh, AA; Zasukhina, GD. (1985). DNA repair synthesis in lymphocytes of people contacting chromium compounds in industry. Cytology and Genetics 19: 68–69.
Runfola, M; Rossi, S; Panunzi, S; Spada, PL; Gui, D. (2003). Botulinum toxin in gastric submucosa reduces stimulated HCl production in rats. BMC Gastroenterol 3: 26. 10.1186/1471-230X-3-26.12964945
Russell, TL; Berardi, RR; Barnett, JL; Dermentzoglou, LC; Jarvenpaa, KM; Schmaltz, SP; Dressman, JB. (1993). Upper gastrointestinal pH in seventy-nine healthy, elderly, North American men and women. Pharm Res 10: 187–196. 10.1023/A:1018970323716.8456064
Russo, P; Catassi, A; Cesario, A; Imperatori, A; Rotolo, N; Fini, M; Granone, P; Dominioni, L. (2005). Molecular mechanisms of hexavalent chromium-induced apoptosis in human bronchoalveolar cells. Am J Respir Cell Mol Biol 33: 589–600. 10.1165/rcmb.2005-0213OC.16166740
Rydén, E; Ekström, C; Hellmér, L; Bolcsfoldi, G. (2000). Comparison of the sensitivities of Salmonella typhimurium strains TA102 and TA2638A to 16 mutagens. Mutagenesis 15: 495–502.11077001
Sakurai, H; Takechi, K; Tsuboi, H; Yasui, H. (1999). ESR characterization and metallokinetic analysis of Cr(V) in the blood of rats given carcinogen chromate(VI) compounds. J Inorg Biochem 76: 71–80.10530008
Salg, J; Alterman, T. (2005). A proportionate mortality study of bricklayers and allied craftworkers. Am J Ind Med 47: 10–19. 10.1002/ajim.20115.15597362
Salnikow, K; Zhitkovich, A; Costa, M. (1992). Analysis of the binding sites of chromium to DNA and protein in vitro and in intact cells. Carcinogenesis 13: 2341–2346. 10.1093/carcin/13.12.2341.1473242
Samuel, JB; Stanley, JA; Sekar, P; Princess, RA; Sebastian, MS; Aruldhas, MM. (2012). Persistent hexavalent chromium exposure impaired the pubertal development and ovarian histoarchitecture in wistar rat offspring. Environ Toxicol 29: 814–828. 10.1002/tox.21810.22936640
Sánchez-Martín, FJ; Fan, Y; Carreira, V; Ovesen, JL; Vonhandorf, A; Xia, Y; Puga, A. (2015). Long-term coexposure to hexavalent chromium and B[a]P causes tissue-specific differential biological effects in liver and gastrointestinal tract of mice. Toxicol Sci 146: 52–64. 10.1093/toxsci/kfv070.25820237
Sankaramanivel, S; Jeyapriya, R; Hemalatha, D; Djody, S; Arunakaran, J; Srinivasan, N. (2006). Effect of chromium on vertebrae, femur and calvaria of adult male rats. Hum Exp Toxicol 25: 311–318.16866188
Santibañez, M; Alguacil, J; de La Hera, MG; Navarrete-Muñoz, EM; Llorca, J; Aragonés, N; Kauppinen, T; Vioque, J; Group, PS. (2012). Occupational exposures and risk of stomach cancer by histological type. Occup Environ Med 69: 268–275. 10.1136/oemed-2011-100071.22068174
Santibanez, M; Vioque, J; Alguacil, J; Barber, X; de la Hera, G; Kauppinen, T. (2008). Occupational exposures and risk of oesophageal cancer by histological type: a case-control study in eastern Spain. Occup Environ Med 65: 774–781. 10.1136/oem.2007.037929.18614460
Santonen, T; Louro, H; Bocca, B; Bousoumah, R; Duca, RC; Fucic, A; Galea, KS; Godderis, L; Göen, T; Iavicoli, I; Janasik, B; Jones, K; Leese, E; Leso, V; Ndaw, S; Poels, K; Porras, SP; Ruggieri, F; Silva, MJ; ... Viegas, S. (2023). The HBM4EU chromates study - Outcomes and impacts on EU policies and occupational health practices [Review]. Int J Hyg Environ Health 248: 114099. 10.1016/j.ijheh.2022.114099.36528954
Santonen, T; Porras, SP; Bocca, B; Bousoumah, R; Duca, RC; Galea, KS; Godderis, L; Göen, T; Hardy, E; Iavicoli, I; Janasik, B; Jones, K; Leese, E; Leso, V; Louro, H; Majery, N; Ndaw, S; Pinhal, H; Ruggieri, F; Silva, MJ; van Nieuwenhuyse, A; Verdonck, J; Viegas, S; Wasowicz, W; Sepai, O; Scheepers, PTJ; team, HEcs. (2022). HBM4EU chromates study - Overall results and recommendations for the biomonitoring of occupational exposure to hexavalent chromium. Environ Res 204: 111984. 10.1016/j.envres.2021.111984.34492275
Sarlinova, M; Majerova, L; Matakova, T; Musak, L; Slovakova, P; Skereňová, M; Kavcová, E; Halašová, E. (2015). Polymorphisms of DNA repair genes and lung cancer in chromium exposure. Adv Exp Med Biol 833: 1–8. 10.1007/5584_2014_82.25300687
Sarto, F; Cominato, I; Bianchi, V; Levis, AG. (1982). Increased incidence of chromosomal aberrations and sister chromatid exchanges in workers exposed to chromic acid (CrO3) in electroplating factories. Carcinogenesis 3: 1011–1016. 10.1093/carcin/3.9.1011.7139855
Sarto, F; Tomanin, R; Giacomelli, L; Iannini, G; Cupiraggi, AR. (1990). The micronucleus assay in human exfoliated cells of the nose and mouth: Application to occupational exposures to chromic acid and ethylene oxide. Mutat Res 244: 345–351. 10.1016/0165-7992(90)90083-V.2385249
Sasaki, YF; Nishidate, E; Izumiyama, F; Matsusaka, N; Tsuda, S. (1997). Simple detection of chemical mutagens by the alkaline single-cell gel electrophoresis (Comet) assay in multiple mouse organs (liver, lung, spleen, kidney, and bone marrow). Mutat Res Genet Toxicol Environ Mutagen 391: 215–231. 10.1016/S1383-5718(97)00073-9.
Sasso, AF; Schlosser, PM. (2015). An evaluation of in vivo models for toxicokinetics of hexavalent chromium in the stomach. Toxicol Appl Pharmacol 287: 293–298. 10.1016/j.taap.2015.06.016.26123277
Sato, S; Takizawa, H; Inui, N. (1990). A comparison of micronucleus induction in 3 mouse strains with representative clastogens. Toxicol Lett 52: 215–220.2378005
Satoh, K; Fukuda, Y; Torii, K; Katsuno, N. (1981). Epidemiological study of workers engaged in the manufacture of chromium compounds. J Occup Med 23: 835–838.
Savitz, DA. (1993). Is statistical significance testing useful in interpreting data? [Review]. Reprod Toxicol 7: 95–100.
Sawicka, E; Długosz, A. (2017). The role of 17β-estradiol metabolites in chromium-induced oxidative stress. Advances in Clinical and Experimental Medicine 26: 215–221. 10.17219/acem/62217.28791837
Sawicka, E; Piwowar, A; Musiala, T; Dlugosz, A. (2017). THE ESTROGENS / CHROMIUM INTERACTION IN THE NITRIC OXIDE GENERATION. Acta Pol Pharm 74: 785–791.29513947
Saxena, DK; Murthy, RC; Jain, VK; Chandra, SV. (1990). Fetoplacental-maternal uptake of hexavalent chromium administered orally in rats and mice. Bull Environ Contam Toxicol 45: 430–435. 10.1007/BF01701168.2257339
Sayato, Y; Nakamuro, K; Matsui, S; Ando, M. (1980). Metabolic fate of chromium compounds. I. Comparative behavior of chromium in rat administered with Na251CrO4 and 51CrCl3. J Pharmacobio-Dyn 3: 17–23. 10.1248/bpb1978.3.17.7205529
Sazakli, E; Villanueva, CM; Kogevinas, M; Maltezis, K; Mouzaki, A; Leotsinidis, M. (2014). Chromium in Drinking Water: Association with Biomarkers of Exposure and Effect. Int J Environ Res Public Health 11: 10125–10145. 10.3390/ijerph111010125.25268509
Scarpignato, C; Girone, MG; Tirelli, F; Bertaccini, G. (1984). Inhibition of gastric emptying and secretion by pirenzepine and atropine in rats. Eur J Pharmacol 101: 193–200. 10.1016/0014-2999(84)90156-0.6547908
Schlosser, PM; Sasso, AF. (2014). A revised model of ex-vivo reduction of hexavalent chromium in human and rodent gastric juices. Toxicol Appl Pharmacol 280: 352–361. 10.1016/j.taap.2014.08.010.25151221
Schoonjans, R; Van Vlem, B; Van Heddeghem, N; Vandamme, W; Vanholder, R; Lameire, N; Lefebvre, R; De Vos, M. (2002). The 13C-octanoic acid breath test: validation of a new noninvasive method of measuring gastric emptying in rats. Neurogastroenterol Motil 14: 287–293. 10.1046/j.1365-2982.2002.00334.x.12061914
Sciannameo, V; Ricceri, F; Soldati, S; Scarnato, C; Gerosa, A; Giacomozzi, G; D'Errico, A. (2019). Cancer mortality and exposure to nickel and chromium compounds in a cohort of Italian electroplaters. Am J Ind Med 62: 99–110. 10.1002/ajim.22941.30615207
Sciome (Sciome, LLC.). (2018). BMDExpress 2 software (Version 44) [Computer Program]. Research Triangle Park, NC: National Toxicology Program. Retrieved from https://www.sciome.com/bmdexpress/
Scott, P; Anderson, K; Singhania, M; Cormier, R. (2020). Cystic Fibrosis, CFTR, and Colorectal Cancer [Review]. International Journal of Molecular Sciences 21. 10.3390/ijms21082891.
Sehlmeyer, U; Hechtenberg, S; Klyszcz, H; Beyersmann, D. (1990). Accumulation of chromium in Chinese hamster V79-cells and nuclei. Arch Toxicol 64: 506–508. 10.1007/BF01977636.2275608
Sekihashi, K; Sasaki, T; Yamamoto, A; Kawamura, K; Ikka, T; Tsuda, S; Sasaki, YF. (2001). A comparison of intraperitoneal and oral gavage administration in comet assay in mouse eight organs. Mutat Res 493: 39–54. 10.1016/S1383-5718(01)00157-7.11516714
Sellappa, S; Prathyumnan, S; Keyan, KS; Joseph, S; Vasudevan, BS; Sasikala, K. (2010). Evaluation of DNA damage induction and repair inhibition in welders exposed to hexavalent chromium. Asian Pac J Cancer Prev 11: 95–100.20593913
Sen, P; Conway, K; Costa, M. (1987). Comparison of the localization of chromosome damage induced by calcium chromate and nickel compounds. Cancer Res 47: 2142–2147.3829003
Sengupta, T; Chattopadhyay, D; Ghosh, N; Das, M; Chatterjee, GC. (1990). Effect of chromium administration on glutathione cycle of rat intestinal epithelial cells. Indian J Exp Biol 28: 1132–1135.2099328
Seo, K; Lee, C. (1993). Mutagenicity of metal compounds using Escherichia. 31: 527–531.
Seoane, AI; Dulout, FN. (1999). Contribution to the validation of the anaphase-telophase test: Aneugenic and clastogenic effects of cadmium sulfate, potassium dichromate and nickel chloride in Chinese hamster ovary cells. Genet Mol Biol 22: 551–555.
Seoane, AI; Dulout, FN. (2001). Genotoxic ability of cadmium, chromium and nickel salts studied by kinetochore staining in the cytokinesis-blocked micronucleus assay. Mutat Res 490: 99–106. 10.1016/S1383-5718(00)00145-5.11342235
Seoane, AI; Güerci, AM; Dulout, FN. (2002). Malsegregation as a possible mechanism of aneuploidy induction by metal salts in MRC-5 human cells. Environ Mol Mutagen 40: 200–206. 10.1002/em.10110.12355554
Seta, JA; Sundin, DS; Pedersen, DH. (1988). NOES National Occupational Exposure Survey Field Guidelines. (88–106). Cincinnati, OH: National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/default.html.
Sharma, P; Bihari, V; Agarwal, SK; Goel, SK. (2012). Genetic predisposition for dermal problems in hexavalent chromium exposed population. Journal of Nucleic Acids 2012: 968641. 10.1155/2012/968641.22919465
Shaw Environmental (Shaw Environmental, Inc). (2006). Final report. Industry profile, exposure profile, technological feasibility evaluation, and environmental impact for industries affected by a revised OSHA standard for hexavalent chromium (General industry, construction, and maritime sectors). (OSHA-H054A-2006–0064-2537). Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. https://www.regulations.gov/document?D=OSHA-H054A-2006-0064-2537.
Shindo, Y; Toyoda, Y; Kawamura, K; Kurebe, M; Shimada, H; Hattori, C; Satake, S. (1989). Micronucleus test with potassium chromate(VI) administered intraperitoneally and orally to mice. Mutat Res 223: 403–406.2747727
Shixiong, C. (1994). [Epidemiological investigation on lung cancer incidence of workers in chromate production]. Zhongguo Gongye Yixue Zazhi/Chinese Journal of Industrial Medicine (6).
Shobana, N; Aruldhas, MM; Tochhawng, L; Loganathan, A; Balaji, S; Kumar, MK; Banu, LAS; Navin, AK; Mayilvanan, C; Ilangovan, R; Balasubramanian, K. (2017). Transient gestational exposure to drinking water containing excess hexavalent chromium modifies insulin signaling in liver and skeletal muscle of rat progeny. Chem Biol Interact 277: 119–128. 10.1016/j.cbi.2017.09.003.28911802
Shobana, N; Kumar, MK; Navin, AK; Akbarsha, MA; Aruldhas, MM. (2020). Prenatal exposure to excess chromium attenuates transcription factors regulating expression of androgen and follicle stimulating hormone receptors in Sertoli cells of prepuberal rats. Chem Biol Interact 328: 109188. 10.1016/j.cbi.2020.109188.32679048
Shrivastava, R; Srivastava, S; Upreti, RK; Chaturvedi, UC. (2005a). Effects of dengue virus infection on peripheral blood cells of mice exposed to hexavalent chromium with drinking water. Indian J Med Res 122: 111–119.16177467
Shrivastava, R; Upreti, RK; Chaturvedi, UC. (2003). Various cells of the immune system and intestine differ in their capacity to reduce hexavalent chromium. FEMS Immunol Med Microbiol 38: 65–70.12900057
Shrivastava, R; Upreti, RK; Chaturvedi, UC. (2005b). Effects of dengue virus infection on the spleen of male mice given hexavalent chromium with drinking water. Toxicol Mech Meth 15: 323–329. 10.1080/153765291009732.
Shumilla, JA; Barchowsky, A. (1999). Inhibition of protein synthesis by chromium(VI) differentially affects expression of urokinase and its receptor in human type II pneumocytes. Toxicol Appl Pharmacol 158: 288–295. 10.1006/taap.1999.8704.10438662
Shumilla, JA; Broderick, RJ; Wang, Y; Barchowsky, A. (1999). Chromium(VI) inhibits the transcriptional activity of nuclear factor-kappaB by decreasing the interaction of p65 with cAMP-responsive element-binding protein-binding protein. J Biol Chem 274: 36207–36212. 10.1074/jbc.274.51.36207.10593907
Silverstein, M; Maizlish, N; Park, R; Mirer, F. (1985). Mortality among workers exposed to coal tar pitch volatiles and welding emissions an exercise in epidemiologic triage. Am J Public Health 75: 1283–1287. 10.2105/ajph.75.11.1283.4051064
Silverstein, M; Mirer, F; Kotelchuck, D; Silverstein, B; Bennett, M. (1981). Mortality among workers in a die-casting and electroplating plant. Scand J Work Environ Health 7: 156–165.7330627
Simonato, L; Fletcher, AC; Andersen, A; Anderson, K; Becker, N; Chang-Claude, J; Ferro, G; Gérin, M; Gray, CN; Hansen, KS. (1991). A historical prospective study of European stainless steel, mild steel, and shipyard welders. Br J Ind Med 48: 145–154. 10.1136/oem.48.3.145.2015204
Singh, I. (1983). Induction of reverse mutation and mitotic gene conversion by some metal compounds in Saccharomyces cerevisiae. Mutat Res 117: 149–152. 10.1016/0165-1218(83)90162-3.6339905
Singhal, VK; Deswal, BS; Singh, BN. (2015). Study of skin and mucous membrane disorders among workers engaged in the sodium dichromate manufacturing industry and chrome plating industry. Indian J Occup Environ Med 19: 129–133. 10.4103/0019-5278.173994.26957809
Sivakumar, KK; Stanley, JA; Arosh, JA; Pepling, ME; Burghardt, RC; Banu, SK. (2014). Prenatal exposure to chromium induces early reproductive senescence by increasing germ cell apoptosis and advancing germ cell cyst breakdown in the F1 offspring. Dev Biol 388: 22–34. 10.1016/j.ydbio.2014.02.003.24530425
Sivakumar, KK; Stanley, JA; Behlen, JC; Wuri, L; Dutta, S; Wu, J; Arosh, JA; Banu, SK. (2022). Inhibition of Sirtuin-1 hyperacetylates p53 and abrogates Sirtuin-1-p53 interaction in Cr(VI)-induced apoptosis in the ovary. Reprod Toxicol 109: 121–134. 10.1016/j.reprotox.2022.03.007.35307491
Sjödahl, K; Jansson, C; Bergdahl, IA; Adami, J; Boffetta, P; Lagergren, J. (2007). Airborne exposures and risk of gastric cancer: a prospective cohort study. Int J Cancer 120: 2013–2018. 10.1002/ijc.22566.17266028
Sjögren, B; Gustavsson, A; Hedström, L. (1987). Mortality in two cohorts of welders exposed to high- and low-levels of hexavalent chromium. Scand J Work Environ Health 13: 247–251. 10.5271/sjweh.2056.3616554
Sjogren, B; Hedstrom, L; Ulfvarson, U. (1983). Urine chromium as an estimator of air exposure to stainless steel welding fumes. Int Arch Occup Environ Health 51: 347–354.6862648
Skowronski, GA; Seide, M; Abdel-Rahman, MS. (2001). Oral bioaccessibility of trivalent and hexavalent chromium in soil by simulated gastric fluid. J Toxicol Environ Health A 63: 351–362. 10.1080/15287390152103652.11471866
Smailyte, G; Kurtinaitis, J; Andersen, A. (2004). Mortality and cancer incidence among Lithuanian cement producing workers. Occup Environ Med 61: 529–534. 10.1136/oem.2003.009936.15150393
Smith, MT; Guyton, KZ; Gibbons, CF; Fritz, JM; Portier, CJ; Rusyn, I; Demarini, DM; Caldwell, JC; Kavlock, RJ; Lambert, PF; Hecht, SS; Bucher, J. R.; Stewart, BW; Baan, RA; Cogliano, VJ; Straif, K. (2016). Key characteristics of carcinogens as a basis for organizing data on mechanisms of carcinogenesis [Review]. Environ Health Perspect 124: 713–721. 10.1289/ehp.1509912.26600562
Smyth, GK; Altman, NS. (2013). Separate-channel analysis of two-channel microarrays: Recovering inter-spot information. BMC Bioinformatics 14: 165. 10.1186/1471-2105–14-165.23705896
Snyder, CA; Udasin, I; Waterman, SJ; Toioli, E; Gochfeld, M. (1996). Reduced IL-6 levels among individuals in Hudson County, New Jersey, an area contaminated with chromium. Arch Environ Health 51: 26–28. 10.1080/00039896.1996.9935989.8629859
Snyder, CA; Valle, CD. (1991). Immune function assays as indicators of chromate exposure. Environ Health Perspect 92: 83–86. 10.1289/ehp.919283.1834456
Snyder, RD. (1988). Role of active oxygen species in metal-induced DNA strand breakage in human diploid fibroblasts. Mutat Res DNA Repair 193: 237–246. 10.1016/0167-8817(88)90034-X.3362151
Sobaszek, A; Edme, JL; Boulenguez, C; Shirali, P; Mereau, M; Robin, H; Haguenoer, JM. (1998). Respiratory symptoms and pulmonary function among stainless steel welders. J Occup Environ Med 40: 223–229.9531093
Sognier, MA; Lu, LW; Lu, TT; Kuo, CM; Alcock, NW; Ramanujam, VS. (1991). Uptake/persistence of chromium compounds in Chinese hamster V79 cells [Abstract]. Environ Mol Mutagen 17: 69.
Song, Y; Wang, T; Pu, J; Guo, J; Chen, Z; Wang, Y; Jia, G. (2014). Multi-element distribution profile in Sprague-Dawley rats: effects of intratracheal instillation of Cr(VI) and Zn intervention. Toxicol Lett 226: 198–205. 10.1016/j.toxlet.2014.02.008.24560605
Sora, S; Agostoni Carbone, ML; Pacciarini, M; Magni, GE. (1986). Disomic and diploid meiotic products induced in Saccharomyces cerevisiae by the salts of 27 elements. Mutagenesis 1: 21–28. 10.1093/mutage/1.1.21.3325730
Sorahan, T; Burges, DC; Hamilton, L; Harrington, JM. (1998). Lung cancer mortality in nickel/chromium platers, 1946–95. Occup Environ Med 55: 236–242. 10.1136/oem.55.4.236.9624277
Sorahan, T; Burges, DCL; Waterhouse, JAH. (1987). A mortality study of nickel/chromium platers. Br J Ind Med 44: 250–258.3567099
Sorahan, T; Cooke, MA. (1989). Cancer mortality in a cohort of United Kingdom steel foundry workers: 1946–85. Br J Ind Med 46: 74–81. 10.1136/oem.46.2.74.2923828
Sorahan, T; Faux, AM; Cooke, MA. (1994). Mortality among a cohort of United Kingdom steel foundry workers with special reference to cancers of the stomach and lung, 1946–90. Occup Environ Med 51: 316–322. 10.1136/oem.51.5.316.8199681
Sorahan, T; Harrington, JM. (2000). Lung cancer in Yorkshire chrome platers, 1972–97. Occup Environ Med 57: 385–389.10810127
Speer, RM; Meaza, I; Toyoda, JH; Lu, Y; Xu, Q; Walter, RB; Kong, M; Lu, H; Kouokam, JC; Wise, JP. (2022). Particulate hexavalent chromium alters microRNAs in human lung cells that target key carcinogenic pathways. Toxicol Appl Pharmacol 438: 115890. 10.1016/j.taap.2022.115890.35101437
Speer, RM; Toyoda, JH; Croom-Perez, TJ; Liu, KJ; Wise, JP. (2021). Particulate hexavalent chromium inhibits E2F1 leading to reduced RAD51 nuclear foci formation in human lung cells. Toxicol Sci 181: 35–46. 10.1093/toxsci/kfab019.33677506
Spiteri, NJ. (1982). Circadian patterning of feeding, drinking and activity during diurnal food access in rats. Physiol Behav 28: 139–147. 10.1016/0031-9384(82)90115-9.7200613
Standeven, AM; Wetterhahn, KE. (1991a). Ascorbate is the principal reductant of chromium (VI) in rat liver and kidney ultrafiltrates. Carcinogenesis 12: 1733–1737. 10.1093/carcin/12.9.1733.1893533
Standeven, AM; Wetterhahn, KE. (1991b). Possible role of glutathione in chromium(VI) metabolism and toxicity in rats. Pharmacol Toxicol 68: 469–476. 10.1111/j.1600-0773.1991.tb01272.x.1891442
Standeven, AM; Wetterhahn, KE. (1992). Ascorbate is the principal reductant of chromium(VI) in rat lung ultrafiltrates and cytosols, and mediates chromium-DNA binding in vitro. Carcinogenesis 13: 1319–1324. 10.1093/carcin/13.8.1319.1499083
Stanley, JA; Lee, J; Nithy, TK; Arosh, JA; Burghardt, RC; Banu, SK. (2011). Chromium-VI arrests cell cycle and decreases granulosa cell proliferation by down-regulating cyclin-dependent kinases (CDK) and cyclins and up-regulating CDK-inhibitors. Reprod Toxicol 32: 112–123. 10.1016/j.reprotox.2011.05.007.21621607
Stanley, JA; Sivakumar, KK; Arosh, JA; Burghardt, RC; Banu, SK. (2014). Edaravone mitigates hexavalent chromium-induced oxidative stress and depletion of antioxidant enzymes while estrogen restores antioxidant enzymes in the rat ovary in F1 offspring. Biol Reprod 91: 12. 10.1095/biolreprod.113.113332.24804965
Stanley, JA; Sivakumar, KK; Nithy, TK; Arosh, JA; Hoyer, PB; Burghardt, RC; Banu, SK. (2013). Postnatal exposure to chromium through mother's milk accelerates follicular atresia in F1 offspring through increased oxidative stress and depletion of antioxidant enzymes. Free Radic Biol Med 61: 179–196. 10.1016/j.freeradbiomed.2013.02.006.23470461
Steenland, K. (2002). Ten-year update on mortality among mild-steel welders. Scand J Work Environ Health 28: 163–167.12109555
Steenland, K; Beaumont, J; Elliot, L. (1991). Lung-cancer in mild-steel welders. Am J Epidemiol 133: 220–229. 10.1093/oxfordjournals.aje.a115866.2000839
Steinhoff, D; ShC, G; Hatfield, GK; Mohr, U. (1986). Carcinogenicity study with sodium dichromate in rats. Exp Toxicol Pathol 30: 129–141. 10.1016/S0232-1513(86)80085-8.
Stella, M; Montaldi, A; Rossi, R; Rossi, G; Levis, AG. (1982). Clastogenic effects of chromium on human lymphocytes in vitro and in vivo. Mutat Res Genet Toxicol 101: 151–164. 10.1016/0165-1218(82)90005-2.
Stellman, SD; Garfinkel, L. (1984). Cancer mortality among woodworkers. Am J Ind Med 5: 343–357. 10.1002/ajim.4700050503.6720695
Stern, AH; Yu, CH; Black, K; Lin, L; Lioy, PJ; Gochfeld, M; Fan, ZH. (2010). Hexavalent chromium in house dust--a comparison between an area with historic contamination from chromate production and background locations. Sci Total Environ 408: 4993–4998. 10.1016/j.scitotenv.2010.07.035.20692023
Stern, F; Lehman, E; Ruder, A. (2001). Mortality among unionized construction plasterers and cement masons. Am J Ind Med 39: 373–388.11323787
Stern, FB. (2003). Mortality among chrome leather tannery workers: an update. Am J Ind Med 44: 197–206. 10.1002/ajim.10242.12874853
Stern, FB; Beaumont, JJ; Halperin, WE; Murthy, LI; Hills, BW; Fajen, JM. (1987). Mortality of chrome leather tannery workers and chemical exposures in tanneries. Scand J Work Environ Health 13: 108–117. 10.5271/sjweh.2073.3602964
Sterne, JAC; Smith, GD; Cox, DR. (2001). Sifting the evidence -- whaťs wrong with significance tests? Br Med J 322: 226–231.11159626
Stohs, SJ; Bagchi, D; Hassoun, E; Bagchi, M. (2001). Oxidative mechanisms in the toxicity of chromium and cadmium ions. J Environ Pathol Toxicol Oncol 20: 201–213. 10.1615/JEnvironPatholToxicolOncol.v20.i2.10.
Subramanian, S; Rajendiran, G; Sekhar, P; Gowri, C; Govindarajulu, P; Aruldhas, MM. (2006). Reproductive toxicity of chromium in adult bonnet monkeys (Macaca radiata Geoffrey). Reversible oxidative stress in the semen. Toxicol Appl Pharmacol 215: 237–249. 10.1016/j.taap.2006.03.004.16678873
Sudha, S; Kripa, SK; Shibily, P; Joseph, S; Balachandar, V. (2011). Biomonitoring of genotoxic effects among shielded manual metal arc welders. Asian Pac J Cancer Prev 12: 1041–1044.21790248
Sugiyama, M; Costa, M; Nakagawa, T; Hidaka, T; Ogura, R. (1988). Stimulation of polyadenosine diphosphoribose synthesis by DNA lesions induced by sodium chromate in Chinese hamster V-79 cells. Cancer Res 48: 1100–1104.3342393
Sugiyama, M; Lin, XH; Costa, M. (1991). Protective effect of vitamin E against chromosomal aberrations and mutation induced by sodium chromate in Chinese hamster V79 cells. Mutat Res 260: 19–23. 10.1016/0165-1218(91)90076-X.2027337
Sugiyama, M; Tsuzuki, K; Lin, X; Costa, M. (1992). Potentiation of sodium chromate(VI)-induced chromosomal aberrations and mutation by vitamin B2 in Chinese hamster V79 cells. Mutat Res 283: 211–214. 10.1016/0165-7992(92)90109-u.1383790
Suh, M; Thompson, CM; Kirman, CR; Carakostas, MC; Haws, LC; Harris, MA; Proctor, DM. (2014). High concentrations of hexavalent chromium in drinking water alter iron homeostasis in F344 rats and B6C3F1 mice. Food Chem Toxicol 65: 381–388. 10.1016/j.fct.2014.01.009.24418189
Sun, H; Clancy, HA; Kluz, T; Zavadil, J; Costa, M. (2011). Comparison of gene expression profiles in chromate transformed BEAS-2B cells. PLoS ONE 6: e17982. 10.1371/journal.pone.0017982.21437242
Sun, H; M, C. (2021). Chromium. In GF Nordberg; M Costa (Eds.), Handbook on the toxicology of metals: Volume II: Specific metals (5th ed., pp. 197–220). Amsterdam, Netherlands: Elsevier.
Sun, H; Zhou, X; Chen, HB; Li, Q; Costa, M. (2009). Modulation of histone methylation and MLH1 gene silencing by hexavalent chromium. Toxicol Appl Pharmacol 237: 258–266. 10.1016/j.taap.2009.04.008.19376149
Sun, J; Kubota, H; Hisanaga, N; Shibata, E; Kamijima, M; Nakamura, K. (2002). Mortality among Japanese construction workers in Mie Prefecture. Occup Environ Med 59: 512–516. 10.1136/oem.59.8.512.12151606
Susa, N; Ueno, S; Furukawa, Y; Michiba, N; Minoura, S. (1989). Induction of lipid peroxidation in mice by hexavalent chromium and its relation to the toxicity. Nihon Juigaku Zasshi 51: 1103–1110. 10.1292/jvms1939.51.1103.2601225
Susa, N; Ueno, S; Furukawa, Y; Sunaga, S; Taruta, Y; Sato, K. (1988). Effect of combined administration of DL-penicillamine and potassium dichromate on lethality, distribution and excretion of chromium in mice. Kitasato Arch Exper Med 61: 51–57.3193681
Sutherland, JE; Zhitkovich, A; Kluz, T; Costa, M. (2000). Rats retain chromium in tissues following chronic ingestion of drinking water containing hexavalent chromium. Biol Trace Elem Res 74: 41–53. 10.1385/BTER:74:1:41.11049199
Suzuki, T; Matsumoto, K; Honma, M; Nohmi, T. (2018). Impact of DNA polymerase ζ mutations on genotoxic thresholds of oxidative mutagens. Mutat Res 828: 10–14. 10.1016/j.mrgentox.2018.02.001.
Suzuki, Y. (1988a). Reduction of hexavalent chromium by ascorbic acid in rat lung lavage fluid. Arch Toxicol 62: 116–122. 10.1007/BF00570129.3196146
Suzuki, Y. (1988b). Valence states of plasma chromium in rats after intraperitoneal administration of sodium chromate. Ind Health 26: 153–157. 10.2486/indhealth.26.153.3403308
Suzuki, Y; Fukuda, K. (1990). Reduction of hexavalent chromium by ascorbic acid and glutathione with special reference to the rat lung. Arch Toxicol 64: 169–176. 10.1007/BF02010721.2372230
Suzuki, Y; Homma, K; Minami, M; Yoshikawa, H. (1984). Distribution of chromium in rats exposed to hexavalent chromium and trivalent chromium aerosols. Ind Health 22: 261–277.6526701
Svensson, BG; Englander, V; Akesson, B; Attewell, R; Skerfving, S; Ericson, A; Möller, T. (1989). Deaths and tumors among workers grinding stainless steel. Am J Ind Med 15: 51–59. 10.1002/ajim.4700150107.2929608
Sweeney, MH; Walrath, J; Waxweiler, RJ. (1985). Mortality among retired fur workers dyers dressers tanners and service workers. Scand J Work Environ Health 11: 257–264. 10.5271/sjweh.2222.4059889
SWRCB. Title 22, Division 4, Chapter 14, Article 3: Amendments, (2014).
Symonds, E; Butler, R; Omari, T. (2002). Noninvasive breath tests can detect alterations in gastric emptying in the mouse. Eur J Clin Invest 32: 341–344. 10.1046/j.1365-2362.2002.00991.x.12027874
Symonds, EL; Tran, CD; Butler, RN; Omari, TI. (2008). Gastric emptying is altered with the presence of gastritis. Dig Dis Sci 53: 636–641. 10.1007/s10620-007-9928-8.17763957
Tagliari, KC; Cecchini, R; Vargas, VMF. (2004a). Mutagenicity of chromium VI using the Salmonella microsuspension bioassay. Revista Brasileira de Toxicologia 17: 45–50.
Tagliari, KC; Vargas, VM; Zimiani, K; Cecchini, R. (2004b). Oxidative stress damage in the liver of fish and rats receiving an intraperitoneal injection of hexavalent chromium as evaluated by chemiluminescence. Environ Toxicol Pharmacol 17: 149–157. 10.1016/j.etap.2004.04.001.21782726
Taioli, E; Zhitkovich, A; Kinney, P; Udasin, I; Toniolo, P; Costa, M. (1995). Increased DNA-protein crosslinks in lymphocytes of residents living in chromium-contaminated areas. Biol Trace Elem Res 50: 175–180. 10.1007/BF02785408.8962789
Takahashi, K; Okubo, T. (1990). A prospective cohort study of chromium plating workers in Japan. Arch Environ Health 45: 107–111. 10.1080/00039896.1990.9935934.2334232
Takahashi, Y; Kondo, K; Hirose, T; Nakagawa, H; Tsuyuguchi, M; Hashimoto, M; Sano, T; Ochiai, A; Monden, Y. (2005). Microsatellite instability and protein expression of the DNA mismatch repair gene, hMLH1, of lung cancer in chromate-exposed workers. Mol Carcinog 42: 150–158. 10.1002/mc.20073.15605365
Takashima, T; Shingaki, T; Katayama, Y; Hayashinaka, E; Wada, Y; Kataoka, M; Ozaki, D; Doi, H; Suzuki, M; Ishida, S; Hatanaka, K; Sugiyama, Y; Akai, S; Oku, N; Yamashita, S; Watanabe, Y. (2013). Dynamic analysis of fluid distribution in the gastrointestinal tract in rats: positron emission tomography imaging after oral administration of nonabsorbable marker, [(18)F]Deoxyfluoropoly(ethylene glycol). Mol Pharm 10: 2261–2269. 10.1021/mp300469m.23600944
Takeuchi, K; Ukawa, H; Konaka, A; Kitamura, M; Sugawa, Y. (1998). Effect of nitric oxide-releasing aspirin derivative on gastric functional and ulcerogenic responses in rats: Comparison with plain aspirin. J Pharmacol Exp Ther 286: 115–121.9655849
Tarvainen, L; Kyyronen, P; Kauppinen, T; Pukkala, E. (2008). Cancer of the mouth and pharynx, occupation and exposure to chemical agents in Finland [in 1971–95]. Int J Cancer 123: 653–659. 10.1002/ijc.23286.18470913
Taylor, FH. (1966). The relationship of mortality and duration of employment as reflected by a cohort of chromate workers. Am J Public Health 56: 218–229.
TCEQ (Texas Commission on Environmental Quality). (2014). Development support document for hexavalent chromium (particulate compounds). Austin, TX.
TCEQ (Texas Commission on Environmental Quality). (2016). Development support document for hexavalent chromium oral reference dose. Austin, TX.
TCEQ (Texas Commission on Environmental Quality). (2017). Texas Air Monitoring Information System: Statistical summary report for chromium VI (Tsp) Stp (Version 4.3.2) [Database]. Austin, TX.
TERA (Toxicology Excellence for Risk Assessment). (2012a). Peer review report on the chromium mode of action studies: Mode of action analysis. Cincinnati, OH. https://tera.org/Peer/MOA%20analysis%20peer%20review%20report.pdf.
TERA (Toxicology Excellence for Risk Assessment). (2012b). Peer review report on the chromium mode of action studies: Mutation studies. Cincinnati, OH. https://tera.org/Peer/Chromium/mutation%20peer%20review%20report.pdf.
Tessier, DM; Pascal, LE. (2006). Activation of MAP kinases by hexavalent chromium, manganese and nickel in human lung epithelial cells. Toxicol Lett 167: 114–121. 10.1016/j.toxlet.2006.08.015.17045426
Than, BL; Linnekamp, JF; Starr, TK; Largaespada, DA; Rod, A; Zhang, Y; Bruner, V; Abrahante, J; Schumann, A; Luczak, T; Walter; Niemczyk, A; O'Sullivan, MG; Medema, JP; Fijneman, RJ; Meijer, GA; Van Den Broek, E; Hodges, CA; Scott, PM; Vermeulen, L; Cormier, RT. (2016). CFTR is a tumor suppressor gene in murine and human intestinal cancer. Oncogene 35: 4179–4187. 10.1038/onc.2015.483.
Thomann, RV; Snyder, CA; Squibb, KS. (1994). Development of a pharmacokinetic model for chromium in the rat following subchronic exposure: I. The importance of incorporating long-term storage compartment. Toxicol Appl Pharmacol 128: 189–198. 10.1006/taap.1994.1197.7940533
Thompson, CM; Aardema, MJ; Heintz, MM; Macgregor, JT; Young, RR. (2021). A review of mammalian in vivo genotoxicity of hexavalent chromium: implications for oral carcinogenicity risk assessment [Review]. Crit Rev Toxicol 51: 820–849. 10.1080/10408444.2021.2000934.35060824
Thompson, CM; Fedorov, Y; Brown, DD; Suh, M; Proctor, DM; Kuriakose, L; Haws, LC; Harris, MA. (2012a). Assessment of Cr(VI)-induced cytotoxicity and genotoxicity using high content analysis. PLoS ONE 7: e42720. 10.1371/journal.pone.0042720.
Thompson, CM; Gregory Hixon, J; Proctor, DM; Haws, LC; Suh, M; Urban, JD; Harris, MA. (2012b). Assessment of genotoxic potential of Cr(VI) in the mouse duodenum: An in silico comparison with mutagenic and nonmutagenic carcinogens across tissues. Regul Toxicol Pharmacol 64: 68–76. 10.1016/j.yrtph.2012.05.019.22705708
Thompson, CM; Haws, LC; Harris, MA; Gatto, NM; Proctor, DM. (2011a). Application of the U.S. EPA mode of action framework for purposes of guiding future research: A case study involving the oral carcinogenicity of hexavalent chromium [Review]. Toxicol Sci 119: 20–40. 10.1093/toxsci/kfq320.20947717
Thompson, CM; Kirman, CR; Proctor, DM; Haws, LC; Suh, M; Hays, SM; Hixon, JG; Harris, MA. (2014). A chronic oral reference dose for hexavalent chromium-induced intestinal cancer. J Appl Toxicol 34: 525–536. 10.1002/jat.2907.23943231
Thompson, CM; Proctor, DM; Haws, LC; Hébert, CD; Grimes, SD; Shertzer, HG; Kopec, AK; Hixon, JG; Zacharewski, TR; Harris, MA. (2011b). Investigation of the mode of action underlying the tumorigenic response induced in B6C3F1 mice exposed orally to hexavalent chromium. Toxicol Sci 123: 58–70. 10.1093/toxsci/kfr164.21712504
Thompson, CM; Proctor, DM; Suh, M; Haws, LC; Hébert, CD; Mann, JF; Shertzer, HG; Hixon, JG; Harris, MA. (2012c). Comparison of the effects of hexavalent chromium in the alimentary canal of F344 rats and B6C3F1 mice following exposure in drinking water: implications for carcinogenic modes of action. Toxicol Sci 125: 79–90. 10.1093/toxsci/kfr280.22011396
Thompson, CM; Proctor, DM; Suh, M; Haws, LC; Kirman, CR; Harris, MA. (2013). Assessment of the mode of action underlying development of rodent small intestinal tumors following oral exposure to hexavalent chromium and relevance to humans [Review]. Crit Rev Toxicol 43: 244–274. 10.3109/10408444.2013.768596.23445218
Thompson, CM; Rager, JE; Suh, M; Ring, CL; Proctor, DM; Haws, LC; Fry, RC; Harris, MA. (2016). Transcriptomic responses in the oral cavity of F344 rats and B6C3F1 mice following exposure to Cr(VI): Implications for risk assessment. Environ Mol Mutagen 57: 706–716. 10.1002/em.22064.27859739
Thompson, CM; Seiter, J; Chappell, MA; Tappero, RV; Proctor, DM; Suh, M; Wolf, JC; Haws, LC; Vitale, R; Mittal, L; Kirman, CR; Hays, SM; Harris, MA. (2015a). Synchrotron-based imaging of chromium and γ-H2AX immunostaining in the duodenum following repeated exposure to Cr(VI) in drinking water. Toxicol Sci 143: 16–25. 10.1093/toxsci/kfu206.25352572
Thompson, CM; Wolf, JC; Elbekai, RH; Paranjpe, MG; Seiter, JM; Chappell, MA; Tappero, RV; Suh, M; Proctor, DM; Bichteler, A; Haws, LC; Harris, MA. (2015b). Duodenal crypt health following exposure to Cr(VI): Micronucleus scoring, γ-H2AX immunostaining, and synchrotron X-ray fluorescence microscopy. Mutat Res Genet Toxicol Environ Mutagen 789-790: 61–66. 10.1016/j.mrgentox.2015.05.004.
Thompson, CM; Young, RR; Dinesdurage, H; Suh, M; Harris, MA; Rohr, AC; Proctor, DM. (2017). Assessment of the mutagenic potential of hexavalent chromium in the duodenum of big blue® rats. Toxicol Appl Pharmacol 330: 48–52. 10.1016/j.taap.2017.07.002.28687238
Tian, X; Patel, K; Ridpath, JR; Chen, Y; Zhou, YH; Neo, D; Clement, J; Takata, M; Takeda, S; Sale, J; Wright, FA; Swenberg, JA; Nakamura, J. (2016). Homologous Recombination and Translesion DNA Synthesis Play Critical Roles on Tolerating DNA Damage Caused by Trace Levels of Hexavalent Chromium. PLoS ONE 11: e0167503. 10.1371/journal.pone.0167503.27907204
Tibbitts, J. (2003). Issues related to the use of canines in toxicologic pathology—issues with pharmacokinetics and metabolism. Toxicol Pathol 31: 17–24. 10.1080/01926230390174896.12597427
Timchalk, C; Poet, TS; Lin, Y; Weitz, KK; Zhao, R; Thrall, KD. (2001). Development of an integrated microanalytical system for analysis of lead in saliva and linkage to a physiologically based pharmacokinetic model describing lead saliva secretion. AIHAJ 62: 295–302. 10.1080/15298660108984631.11434435
Toebak, MJ; Pohlmann, PR; Sampat-Sardjoepersad, SC; von Blomberg, BM; Bruynzeel, DP; Scheper, RJ; Rustemeyer, T; Gibbs, S. (2006). CXCL8 secretion by dendritic cells predicts contact allergens from irritants. Toxicol In Vitro 20: 117–124. 10.1016/j.tiv.2005.06.039.16099135
TOMA (Tabershaw Occupational Medicine Associates). (1987). 1978 Cross sectional health study of workers at a wood preserving plant with attachments [TSCA Submission]. (EPA/OTS Doc #86–870001565). https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0516146.
Toniolo, P; Zhitkovich, A; Costa, M. (1993). Development and utilization of a new simple assay for DNA-protein crosslinks as a biomarker of exposure to welding fumes. Int Arch Occup Environ Health 65: S87–S89. 10.1007/BF00381313.8406945
Trzeciak, A; Kowalik, J; Małecka-Panas, E; Drzewoski, J; Wojewódzka, M; Iwaneńko, T; Błasiak, J. (2000). Genotoxicity of chromium in human gastric mucosa cells and peripheral blood lymphocytes evaluated by the single cell gel electrophoresis (comet assay). Med Sci Monit 6: 24–29.11208279
Tsao, DA; Tseng, WC; Chang, HR. (2011). The expression of RKIP, RhoGDI, galectin, c-Myc and p53 in gastrointestinal system of Cr(VI)-exposed rats. J Appl Toxicol 31: 730–740. 10.1002/jat.1621.21437922
Tsapakos, MJ; Hampton, TH; Jennette, KW. (1981). The carcinogen chromate induces DNA crosslinks in rat liver and kidney. J Biol Chem 256: 3623–3626.7217049
Tsapakos, MJ; Hampton, TH; Wetterhahn, KE. (1983). Chromium(VI)-induced DNA lesions and chromium distribution in rat kidney, liver, and lung. Cancer Res 43: 5662–5667.6640521
Tully, DB; Collins, BJ; Overstreet, JD; Smith, CS; Dinse, GE; Mumtaz, MM; Chapin, RE. (2000). Effects of arsenic, cadmium, chromium, and lead on gene expression regulated by a battery of 13 different promoters in recombinant HepG2 cells. Toxicol Appl Pharmacol 168: 79–90. 10.1006/taap.2000.9014.11032763
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1998). Toxicological review of hexavalent chromium [EPA Report] (pp. 80). (630R98009). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0144tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3–25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens [EPA Report]. (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/supplemental-guidance-assessing-susceptibility-early-life-exposure-carcinogens.
U.S. EPA (U.S. Environmental Protection Agency). (2006a). 2006 community water system survey -Volume I: Overview [EPA Report]. (EPA 815-R-09–001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009JJI.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2006b). 2006 community water system survey -Volume II: Detailed tables and survey methodology [EPA Report]. (EPA 815-R-09–002). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://nepis.epa.gov/Exe/ZyPDF.cgi?Dockey=P1009USA.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2007). Framework for determining a mutagenic mode of action for carcinogenicity: Using EPA's 2005 cancer guidelines and supplemental guidance for assessing susceptibility from early-life exposure to carcinogens. External Review Draft [EPA Report]. (EPA 120/R-07/002-A). Washington, DC. http://www.epa.gov/osa/mmoaframework/pdfs/MMOA-ERD-FINAL-83007.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2008). Cr (VI) quantitative risk assessment Q*1 based on mouse carcinogenicity studies. Washington, DC: Health Effects Division, Office of Pesticide Programs. http://www.regulations.gov/#!documentDetail;D=EPA-HQ-OPP-2003–0250-0088.
U.S. EPA (U.S. Environmental Protection Agency). (2009). Inorganic hexavalent chromium (Cr(Vi)): revised report of the cancer assessment review committee.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2012b). The third Unregulated Contaminant Monitoring Rule (UCMR 3). Presentation presented at US EPA Webinar, September, 2012, OGWDW, SRMD Technical Support Center Cincinnati Ohio.
U.S. EPA (U.S. Environmental Protection Agency). (2014a). Choosing number of stages of multistage model for cancer modeling: SOP for contractor and IRIS analysts.
U.S. EPA (U.S. Environmental Protection Agency). (2014b). Preliminary materials for the Integrated Risk Information System (IRIS) toxicological review of hexavalent chromium part 1: Experimental animal studies [CASRN) 18540–29-9] [EPA Report]. (EPA/635/R-14/094). Research Triangle Park, NC. https://www.epa.gov/iris/iris-bimonthly-public-meeting-jun-2014.
U.S. EPA (U.S. Environmental Protection Agency). (2014c). Preliminary materials for the Integrated Risk Information System (IRIS) toxicological review of hexavalent chromium part 2: Human, toxicokinetic, and mechanistic Studies [CASRN) 18540–29-9] [EPA Report]. (EPA/635/R-14/218). Research Triangle Park, NC. https://www.epa.gov/iris/iris-bimonthly-public-meeting-oct-2014.
U.S. EPA (U.S. Environmental Protection Agency). (2014d). The third Unregulated Contaminant Monitoring Rule (UCMR 3) occurrence data. Retrieved from http://water.epa.gov/lawsregs/rulesregs/sdwa/ucmr/data.cfm#ucmr2013
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015.
U.S. EPA (U.S. Environmental Protection Agency). (2018). An umbrella Quality Assurance Project Plan (QAPP) for PBPK models [EPA Report]. (ORD QAPP ID No: B-0030740-QP-1–1). Research Triangle Park, NC.
U.S. EPA (U.S. Environmental Protection Agency). (2019a). Exposure factors handbook chapter 3 (update): Ingestion of water and other select liquids [EPA Report]. (EPA/600/R-18/259F). Washington, DC. https://cfpub.epa.gov/ncea/efp/recordisplay.cfm?deid=343661.
U.S. EPA (U.S. Environmental Protection Agency). (2019b). Systematic Review Protocol for the Hexavalent Chromium IRIS Assessment (Preliminary Assessment Materials) [EPA Report]. (EPA/635/R-18/155).
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Benchmark Dose Software (BMDS). Version 3.2: User guide [EPA Report]. (EPA/600/R-20/216). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10103T2.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2020b). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA/600/R-20/137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Model log files for the IRIS toxicological review of hexavalent chromium.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Supplementary ex vivo model evaluation in support of the Cr(VI) IRIS assessment [Supplemental Data].
U.S. EPA (U.S. Environmental Protection Agency). (2022a). Hierarchical clustering of microarrays from duodenum, jejunum, and palate tissues from mice exposed to SDD for 7 days and 90 days.
U.S. EPA (U.S. Environmental Protection Agency). (2022b). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). PBPK model code for Cr(VI) in the gastric compartment [PBPK].
Uddin, AN; Burns, FJ; Rossman, TG; Chen, H; Kluz, T; Costa, M. (2007). Dietary chromium and nickel enhance UV-carcinogenesis in skin of hairless mice. Toxicol Appl Pharmacol 221: 329–338. 10.1016/j.taap.2007.03.030.17499830
Ueno, S; Kashimoto, T; Susa, N; Furukawa, Y; Ishii, M; Yokoi, K; Yasuno, M; Sasaki, YF; Ueda, J; Nishimura, Y; Sugiyama, M. (2001). Detection of dichromate (VI)-induced DNA strand breaks and formation of paramagnetic chromium in multiple mouse organs. Toxicol Appl Pharmacol 170: 56–62. 10.1006/taap.2000.9081.11141356
Ueno, S; Susa, N; Furukawa, Y. (1990). Uptake and distribution of chromium in isolated rat hepatocytes and its relation to cellular injury. Kitasato Arch Exper Med 63: 49–57.2273759
Ueno, S; Susa, N; Furukawa, Y; Sugiyama, M. (1995). Formation of paramagnetic chromium in liver of mice treated with dichromate (VI). Toxicol Appl Pharmacol 135: 165–171. 10.1006/taap.1995.1219.8545823
Umeda, M; Nishimura, M. (1979). Inducibility of chromosomal aberrations by metal compounds in cultured mammalian cells. DNA Repair 67: 221–229. 10.1016/0165-1218(79)90016-8.
Upreti, RK; Shrivastava, R; Kannan, A; Chaturvedi, UC. (2005). A comparative study on rat intestinal epithelial cells and resident gut bacteria: (I) - Effect of hexavalent chromium. Toxicol Mech Meth 15: 331–338. 10.1080/153765291009804.
Urbaneja Arrúe, F; Aurrekoetxea Agirre, JJ; Echenagusía Capelastegui, V. (1995). [Mortality among steel workers of the Basque Country]. Gac Sanit 9: 287–294. 10.1016/S0213-9111(95)71251-1.8582802
US DHHS. (1990). National Occupational Exposure Survey: Sampling methodology. (DHHS (NIOSH) Publication Number 89–102). Cincinnati, OH: Public Health Service, CDC, NIOSH. https://www.cdc.gov/niosh/docs/89-102/default.html.
Vaglenov, A; Nosko, M; Georgieva, R; Carbonell, E; Creus, A; Marcos, R. (1999). Genotoxicity and radioresistance in electroplating workers exposed to chromium. Mutat Res 446: 23–34.10613183
van Wijngaarden, E; Mundt, KA; Luippold, RS. (2004). Evaluation of the exposure-response relationship of lung cancer mortality and occupational exposure to hexavalent chromium based on published epidemiological data. Nonlinearity Biol Toxicol Med 2: 27–34. 10.1080/15401420490426972.19330106
Vanoirbeek, JA; Hoet, PH; Nemery, B; Verbeken, EK; Haufroid, V; Lison, D; Dinsdale, D. (2003). Kinetics of an intratracheally administered chromium catalyst in rats. J Toxicol Environ Health A 66: 393–409. 10.1080/15287390306366.12554544
Vaquero, J; Briz, O; Herraez, E; Muntané, J; Marin, JJ. (2013). Activation of the nuclear receptor FXR enhances hepatocyte chemoprotection and liver tumor chemoresistance against genotoxic compounds. Biochim Biophys Acta 1833: 2212–2219. 10.1016/j.bbamcr.2013.05.006.23680185
Vasant, C; Balamurugan, K; Rajaram, R; Ramasami, T. (2001). Apoptosis of lymphocytes in the presence of Cr(V) complexes: role in Cr(VI)-induced toxicity. Biochem Biophys Res Commun 285: 1354–1360. 10.1006/bbrc.2001.5335.11478807
Vasant, C; Rajaram, R; Ramasami, T. (2003). Apoptosis of lymphocytes induced by chromium(VI/V) is through ROS-mediated activation of Src-family kinases and caspase-3. Free Radic Biol Med 35: 1082–1100. 10.1016/S0891-5849(03)00471-4.14572611
Vashishat, R; Vasudeva, M. (1987). Genotoxic potential of chromium salts in Saccharomyces cerevisiae. Indian J Microbiol 27: 35–36.
Venier, P; Gava, C; Zordan, M; Bianchi, V; Levis, AG; De Flora, S; Bennicelli, C; Camoirano, A. (1987). Interactions of Chromium with Nitrilotriacetic Acid (NTA) in the Induction of Genetic Effects in Bacteria. Toxicol Environ Chem 14: 201–218. 10.1080/02772248709357204.
Venier, P; Montaldi, A; Majone, F; Bianchi, V; Levis, AG. (1982). Cytotoxic, mutagenic and clastogenic effects of industrial chromium compounds. Carcinogenesis 3: 1331–1338. 10.1093/carcin/3.11.1331.6758977
Venitt, S; Levy, LS. (1974). Mutagenicity of chromates in bacteria and its relevance to chromate carcinogenesis. Nature 250: 493–495.4620019
Verdonck, J; Duca, RC; Galea, KS; Iavicoli, I; Poels, K; Töreyin, ZN; Vanoirbeek, J; Godderis, L. (2021). Systematic review of biomonitoring data on occupational exposure to hexavalent chromium [Review]. Int J Hyg Environ Health 236: 113799. 10.1016/j.ijheh.2021.113799.34303131
Verschoor, MA; Bragt, PC; Herber, RFM; Zielhuis, RL; Zwennis, WCM. (1988). Renal function of chrome-plating workers and welders. Int Arch Occup Environ Health 60: 67–70. 10.1007/BF00409381.3350606
Veyalkin, I; Gerein, V. (2006). Retrospective cohort study of cancer mortality at the Minsk Leather Tannery. Ind Health 44: 69–74.16610537
Veyalkin, IV; Milyutin, AA. (2003). Proportionate cancer mortality among workers in the Belarussian tanning industry. Am J Ind Med 44: 637–642. 10.1002/ajim.10275.14635240
Viegas, S; Martins, C; Bocca, B; Bousoumah, R; Duca, RC; Galea, KS; Godderis, L; Iavicoli, I; Janasik, B; Jones, K; Leese, E; Leso, V; Ndaw, S; van Nieuwenhuyse, A; Poels, K; Porras, SP; Ruggieri, F; Silva, MJ; Verdonck, J; Wasowicz, W; Scheepers, PTJ; Santonen, T; Hbm Eu Chromates Study Team, T. (2022). HBM4EU Chromates Study: Determinants of Exposure to Hexavalent Chromium in Plating, Welding and Other Occupational Settings. Int J Environ Res Public Health 19. 10.3390/ijerph19063683.
Vigliani, EC; Zurlo, N. (1955). Erfahrungen der Clinica del Lavoro mit einigen maximalen Arbeitsplatzkonzentrationen (MAK) von Industriegiften. Int Arch Occup Environ Health 13: 528–534. 10.1007/BF00312756.
Vilcheck, SK; Ceryak, S; O'Brien, TJ; Patierno, S. R. (2006). FANCD2 monoubiquitination and activation by hexavalent chromium [Cr(VI)] exposure: activation is not required for repair of Cr(VI)-induced DSBs. Mutat Res 610: 21–30. 10.1016/j.mrgentox.2006.06.009.16893675
Vilcheck, SK; O'Brien, TJ; Pritchard, DE; Ha, L; Ceryak, S; Fornsaglio, JL; Patierno, S. R. (2002). Fanconi anemia complementation group A cells are hypersensitive to chromium(VI)-induced toxicity. Environ Health Perspect 110 Suppl 5: 773–777. 10.1289/ehp.02110s5773.12426130
Voitkun, V; Zhitkovich, A; Costa, M. (1998). Cr(III)-mediated crosslinks of glutathione or amino acids to the DNA phosphate backbone are mutagenic in human cells. Nucleic Acids Res 26: 2024–2030.9518499
Wada, O; Wu, GY; Yamamoto, A; Manabe, S; Ono, T. (1983). Purification and chromium-excretory function of low-molecular-weight, chromium-binding substances from dog liver. Environ Res 32: 228–239.6617615
Wakeman, TP; Wyczechowska, D; Xu, B. (2005). Involvement of the p38 MAP kinase in Cr(VI)-induced growth arrest and apoptosis. Mol Cell Biochem 279: 69–73. 10.1007/s11010-005-8216-1.16283515
Wakeman, TP; Xu, B. (2006). ATR regulates hexavalent chromium-induced S-phase checkpoint through phosphorylation of SMC1. Mutat Res 610: 14–20. 10.1016/j.mrgentox.2006.06.007.16876463
Wallmark, B; Larsson, H; Humble, L. (1985). The relationship between gastric acid secretion and gastric H+,K+-ATPase activity. J Biol Chem 260: 13681–13684.2997178
Walrath, J; Decouflé, P; Thomas, TL. (1987). Mortality among workers in a shoe manufacturing company. Am J Ind Med 12: 615–623.3687954
Wang, BJ; Sheu, HM; Guo, YL; Lee, YH; Lai, CS; Pan, MH; Wang, YJ. (2010a). Hexavalent chromium induced ROS formation, Akt, NF-kappaB, and MAPK activation, and TNF-alpha and IL-1alpha production in keratinocytes. Toxicol Lett 198: 216–224. 10.1016/j.toxlet.2010.06.024.20619327
Wang, E; Dement, JM; Lipscomb, H. (1999). Mortality among North Carolina construction workers, 1988–1994. Appl Occup Environ Hyg 14: 45–58. 10.1080/104732299303412.10730138
Wang, KS; Komar, AR; Ma, T; Filiz, F; McLeroy, J; Hoda, K; Verkman, AS; Bastidas, JA. (2000). Gastric acid secretion in aquaporin-4 knockout mice. Am J Physiol Gastrointest Liver Physiol 279: G448–G453.10915655
Wang, L; Qiu, JG; He, J; Liu, WJ; Ge, X; Zhou, FM; Huang, YX; Jiang, BH; Liu, LZ. (2019). Suppression of miR-143 contributes to overexpression of IL-6, HIF-1α and NF-κB p65 in Cr(VI)-induced human exposure and tumor growth. Toxicol Appl Pharmacol 378: 114603. 10.1016/j.taap.2019.114603.31152816
Wang, TC; Song, YS; Wang, H; Zhang, J; Yu, SF; Gu, YE; Chen, T; Wang, Y; Shen, HQ; Jia, G. (2012). Oxidative DNA damage and global DNA hypomethylation are related to folate deficiency in chromate manufacturing workers. J Hazard Mater 213–214: 440–446. 10.1016/j.jhazmat.2012.02.024.
Wang, X; Qin, Q; Xu, X; Xu, J; Wang, J; Zhou, J; Huang, S; Zhai, W; Zhou, H; Chen, J. (1994). Chromium-Induced Early Changes in Renal Function among Ferrochromium-Producing Workers. Toxicology 90: 93–101. 10.1016/0300-483X(94)90208-9.7912862
Wang, XF; Lou, XM; Shen, Y; Xing, ML; Xu, LH. (2010b). Apoptotic-related protein changes induced by hexavalent chromium in mice liver. Environ Toxicol 25: 77–82. 10.1002/tox.20478.19219935
Wang, XF; Xing, ML; Shen, Y; Zhu, X; Xu, LH. (2006). Oral administration of Cr(VI) induced oxidative stress, DNA damage and apoptotic cell death in mice. Toxicology 228: 16–23. 10.1016/j.tox.2006.08.005.16979809
Wang, Y; Wu, W; Yao, C; Lou, J; Chen, R; Jin, L; Wu, N; Gao, M; Song, P; Tan, Y; Liu, K. (2015). Elevated tissue Cr levels, increased plasma oxidative markers, and global hypomethylation of blood DNA in male Sprague-Dawley rats exposed to potassium dichromate in drinking water. Environ Toxicol. 10.1002/tox.22117.
Wang, Z; Peng, H; Zhang, R; Jiang, X; Chen, S; Guo, P; Xiao, Y; Zeng, X; Wang, Q; Aschner, M; Chou, WC; Li, D; Chen, W; Chen, L. (2022). Assessment of intestinal injury of hexavalent chromium using a modified in vitro gastrointestinal digestion model. Toxicol Appl Pharmacol 436: 115880. 10.1016/j.taap.2022.115880.35016909
Watanabe, K; Satamoto, K; Sasaki, T. (1998). Comparisons on chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study II. Mutat Res 412: 17–31. 10.1016/S1383-5718(97)00155-1.9508361
Wei, X; Hu, LL; Chen, ML; Yang, T; Wang, JH. (2016). Analysis of the Distribution Pattern of Chromium Species in Single Cells. Anal Chem 88: 12437–12444. 10.1021/acs.analchem.6b03810.28193078
Welinder, H; Littorin, M; Gullberg, B; Skerfving, S. (1983). Elimination of chromium in urine after stainless steel welding. Scand J Work Environ Health 9: 397–403. 10.5271/sjweh.2394.6673098
Welling, R; Beaumont, JJ; Petersen, SJ; Alexeeff, GV; Steinmaus, C. (2015). Chromium VI and stomach cancer: a meta-analysis of the current epidemiological evidence [Review]. Occup Environ Med 72: 151–159. 10.1136/oemed-2014-102178.25231674
Werfel, U; Langen, V; Eickhoff, I; Schoonbrood, J; Vahrenholz, C; Brauksiepe, A; Popp, W; Norpoth, K. (1998). Elevated DNA single-strand breakage frequencies in lymphocytes of welders exposed to chromium and nickel. Carcinogenesis 19: 413–418.9525274
Westberg, H; Andersson, L; Bryngelsson, IL; Ngo, Y; Ohlson, CG. (2013). Cancer morbidity and quartz exposure in Swedish iron foundries. Int Arch Occup Environ Health 86: 499–507. 10.1007/s00420-012-0782-4.22729566
Wetterhahn, KE; Hamilton, JW; Aiyar, J; Borges, KM; Floyd, R. (1989). Mechanism of chromium(VI) carcinogenesis: Reactive intermediates and effect on gene expression [Review]. Biol Trace Elem Res 21: 405–411. 10.1007/BF02917282.2484620
WHO (World Health Organization). (2000). Air quality guidelines for Europe (2nd ed.). Copenhagen, Denmark: World Health Organization, Regional Office for Europe. http://www.euro.who.int/en/health-topics/environment-and-health/air-quality/publications/pre2009/air-quality-guidelines-for-europe.
WHO (World Health Organization). (2003). Chromium in drinking water. (WHO/SDE/WSH/03.04/04). Geneva, Switzerland. http://www.who.int/water_sanitation_health/dwq/chemicals/chromium.pdf.
WHO (World Health Organization). (2020). Chromium in drinking water. (WHO/HEP/ECH/WSH/2020.3).
Wiegand, HJ; Bolt, HM. (1985). Intracellular disposition of chromium-vi in the isolated perfused rat liver [Abstract]. Naunyn-Schmiedebergs Arch Pharmacol 329: R34.
Wiegand, HJ; Ottenwaelder, H. (1985). Molecular mechanisms for the in-vitro reduction of chromium-VI to chromium-III by glutathione and their relevance for the metabolism of chromates [Abstract]. Naunyn-Schmiedebergs Arch Pharmacol 330: R22.
Wiegand, HJ; Ottenwaelder, H; Bolt, HM. (1986a). Possible involvement of the anion transport system band-3-protein in fast chromium-vi uptake of human red blood cells. 332: R27.
Wiegand, HJ; Ottenwalder, H; Bolt, HM. (1987). Bioavailability and metabolism of hexavalent chromium compounds. Toxicol Environ Chem 14: 263–275. 10.1080/02772248709357210.
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1984a). Disposition of intratracheally administered chromium(III) and chromium(VI) in rabbits. Toxicol Lett 22: 273–276. 10.1016/0378-4274(84)90078-X.6548051
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1984b). The reduction of chromium (VI) to chromium (III) by glutathione: An intracellular redox pathway in the metabolism of the carcinogen chromate. Toxicology 33: 341–348. 10.1016/0300-483X(84)90050-7.6515663
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1985). Fast uptake kinetics in vitro of 51Cr (VI) by red blood cells of man and rat. Arch Toxicol 57: 31–34. 10.1007/BF00286571.4015396
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1986b). Disposition of a soluble chromate in the isolated perfused rat liver. Xenobiotica 16: 839–844. 10.3109/00498258609038965.3765662
Wiegand, HJ; Ottenwälder, H; Bolt, HM. (1988). Recent advances in biological monitoring of hexavalent chromium compounds. Sci Total Environ 71: 309–315. 10.1016/0048-9697(88)90202-1.3406703
Wild, D. (1978). Cytogenetic effects in the mouse of 17 chemical mutagens and carcinogens evaluated by the micronucleus test. DNA Repair 56: 319–327.
Williams, RV; DeMarini, DM; Stankowski Jr., LF; Escobar, PA; Zeiger, E; Howe, J; Elespuru, R; Cross, KP. (2019). Are all bacterial strains required by OECD mutagenicity test guideline TG471 needed? Mutat Res Genet Toxicol Environ Mutagen 848. 10.1016/j.mrgentox.2019.503081.
Wise JP, S.,r; Wise, SS; Little, JE. (2002). The cytotoxicity and genotoxicity of particulate and soluble hexavalent chromium in human lung cells. Mutat Res Genet Toxicol Environ Mutagen 517: 221–229. 10.1016/S1383-5718(02)00071-2.
Wise, SS; Holmes, AL; Liou, L; Adam, RM; Wise, JP. (2016). Hexavalent chromium induces chromosome instability in human urothelial cells. Toxicol Appl Pharmacol 296: 54–60. 10.1016/j.taap.2016.02.015.26908176
Wise, SS; Holmes, AL; Xie, H; Thompson, WD; Wise, JP, Sr. (2006). Chronic exposure to particulate chromate induces spindle assembly checkpoint bypass in human lung cells. Chem Res Toxicol 19: 1492–1498. 10.1021/tx0601410.17112237
Witmer, CM; Park, HS; Shupack, SI. (1989). Mutagenicity and disposition of chromium. Sci Total Environ 86: 131–148.2690337
Witt, KL; Knapton, A; Wehr, CM; Hook, GJ; Mirsalis, J; Shelby, MD; Macgregor, JT. (2000). Micronucleated erythrocyte frequency in peripheral blood of B6C3F(1) mice from short-term, prechronic, and chronic studies of the NTP carcinogenesis bioassay program. Environ Mol Mutagen 36: 163–194. 10.1002/1098-2280(2000)36:3<163::AID-EM1>3.0.CO;2-P.11044899
Wong, V; Armknecht, S; Zhitkovich, A. (2012). Metabolism of Cr(VI) by ascorbate but not glutathione is a low oxidant-generating process. 26: 192–196. 10.1016/j.jtemb.2012.04.016.22572042
Wood, CE; Hukkanen, RR; Sura, R; Jacobson-Kram, D; Nolte, T; Odin, M; Cohen, SM. (2015). Scientific and Regulatory Policy Committee (SRPC) Review*: Interpretation and Use of Cell Proliferation Data in Cancer Risk Assessment. Toxicol Pathol 43: 760–775. 10.1177/0192623315576005.25903269
Wroñska-Nofer, T; Wisniewska-Knypl, J; Dziubaltowska, E; Wyszyñska, K. (1999). Prooxidative and genotoxic effect of transition metals (cadmium, nickel, chromium, and vanadium) in mice. Trace Elem Electroly 16: 87–92.
Wu, F; Sun, H; Kluz, T; Clancy, HA; Kiok, K; Costa, M. (2012). Epigallocatechin-3-gallate (EGCG) protects against chromate-induced toxicity in vitro. Toxicol Appl Pharmacol 258: 166–175. 10.1016/j.taap.2011.10.018.22079256
Wu, FY; Tsai, FJ; Kuo, HW; Tsai, CH; Wu, WY; Wang, RY; Lai, JS. (2000). Cytogenetic study of workers exposed to chromium compounds. Mutat Res Genet Toxicol Environ Mutagen 464: 289–296. 10.1016/S1383-5718(99)00206-5.
Wu, FY; Wu, WY; Kuo, HW; Liu, CS; Wang, RY; Lai, JS. (2001). Effect of genotoxic exposure to chromium among electroplating workers in Taiwan. Sci Total Environ 279: 21–28.11712598
Wu, R; Wu, T; Wang, K; Luo, S; Chen, Z; Fan, M; Xue, D; Lu, H; Zhuang, Q; Xu, X. (2018). Prognostic significance of galectin-1 expression in patients with cancer: a meta-analysis [Review]. Canc Cell Int 18: 108. 10.1186/s12935-018-0607-y.
Wultsch, G; Nersesyan, A; Kundi, M; Jakse, R; Beham, A; Wagner, KH; Knasmueller, S. (2014). The sensitivity of biomarkers for genotoxicity and acute cytotoxicity in nasal and buccal cells of welders. Int J Hyg Environ Health 217: 492–498. 10.1016/j.ijheh.2013.09.005.24698449
Wultsch, G; Nersesyan, A; Kundi, M; Mišík, M; Setayesh, T; Waldherr, M; Vodicka, P; Vodickova, L; Knasmüller, S. (2017). Genotoxic and cytotoxic effects in exfoliated buccal and nasal cells of chromium and cobalt exposed electroplaters. J Toxicol Environ Health A 80: 1–10. 10.1080/15287394.2017.1286918.27898270
Xia, B; Yang, LQ; Huang, HY; Pang, L; Hu, GH; Liu, QC; Yuan, JH; Liu, JJ; Xia, YB; Zhuang, ZX. (2011). Chromium(VI) causes down regulation of biotinidase in human bronchial epithelial cells by modifications of histone acetylation. Toxicol Lett 205: 140–145. 10.1016/j.toxlet.2011.05.1032.21641978
Xia, B; Yuan, J; Pang, L; He, K. (2022). Chromium [Cr(VI)] Exposure Causes Cytotoxicity of Human Bronchial Epithelial Cells (16-HBE) and Proteomic Alterations. Int J Toxicol 10915818221078277. 10.1177/10915818221078277.
Xiao, F; Feng, X; Zeng, M; Guan, L; Hu, Q; Zhong, C. (2012a). Hexavalent chromium induces energy metabolism disturbance and p53-dependent cell cycle arrest via reactive oxygen species in L-02 hepatocytes. Mol Cell Biochem 371: 65–76. 10.1007/s11010-012-1423-7.22886373
Xiao, F; Li, Y; Dai, L; Deng, Y; Zou, Y; Li, P; Yang, Y; Zhong, C. (2012b). Hexavalent chromium targets mitochondrial respiratory chain complex I to induce reactive oxygen species-dependent caspase-3 activation in L-02 hepatocytes. Int J Mol Med 30: 629–635. 10.3892/ijmm.2012.1031.22710416
Xiao, F; Li, Y; Luo, L; Xie, Y; Zeng, M; Wang, A; Chen, H; Zhong, C. (2014). Role of mitochondrial electron transport chain dysfunction in Cr(VI)-induced cytotoxicity in L-02 hepatocytes. Cell Physiol Biochem 33: 1013–1025. 10.1159/000358672.24732427
Xiao, Y; Zeng, M; Yin, L; Li, N; Xiao, F. (2019). Clusterin increases mitochondrial respiratory chain complex I activity and protects against hexavalent chromium-induced cytotoxicity in L-02 hepatocytes. Toxicology Research 8: 15–24. 10.1039/c8tx00231b.30713657
Xiaohua, L; Yanshuang, S; Li, W; Yuhui, L; Ji, Z; Yanhui, M; Yun, W; Wenjun, M; Lei, Y; Guang, J. (2012). Evaluation of the correlation between genetic damage and occupational chromate exposure through BNMN frequencies. J Occup Environ Med 54: 166–170. 10.1097/JOM.0b013e31823d86b4.22157804
Xie, Y; Xiao, F; Luo, L; Zhong, C. (2014). Activation of autophagy protects against ROS-mediated mitochondria-dependent apoptosis in L-02 hepatocytes induced by Cr(VI). Cell Physiol Biochem 33: 705–716. 10.1159/000358646.24643125
Xu, J; Bubley, GJ; Detrick, B; Blankenship, LJ; Patierno, SR. (1996a). Chromium(VI) treatment of normal human lung cells results in guanine-specific DNA polymerase arrest, DNA-DNA cross-links and S-phase blockade of cell cycle. Carcinogenesis 17: 1511–1517.8706257
Xu, J; Zhao, M; Pei, L; Zhang, R; Liu, X; Wei, L; Yang, M; Xu, Q. (2018). Oxidative stress and DNA damage in a long-term hexavalent chromium-exposed population in North China: a cross-sectional study. BMJ Open 8: e021470. 10.1136/bmjopen-2017-021470.
Xu, Z; Brown, LM; Pan, GW; Liu, TF; Gao, GS; Stone, BJ; Cao, RM; Guan, DX; Sheng, JH; Yan, ZS; Dosemeci, M; Fraumeni, JF; Blot, WJ. (1996b). Cancer risks among iron and steel workers in Anshan, China, Part II: Case-control studies of lung and stomach cancer. Am J Ind Med 30: 7–15. 10.1002/(SICI)1097-0274(199607)30:1&lt;7::AID-AJIM2&gt;3.0.CO;2-#.8837676
Yamaguchi, S; K, S; Shimojo, N. (1983). On the biological half-time of hexavalent chromium in rats. Ind Health 21: 25–34.6841147
Yamamoto, A; Kohyama, Y; Hanawa, T. (2002). Mutagenicity evaluation of forty-one metal salts by the umu test. J Biomed Mater Res 59: 176–183. 10.1002/jbm.123.11745551
Yamamoto, A; Wada, O; Ono, T. (1981). A low-molecular-weight, chromium-binding substance in mammals. Toxicol Appl Pharmacol 59: 515–523.7268774
Yang, F; Zhao, L; Mei, D; Jiang, L; Geng, C; Li, Q; Yao, X; Liu, Y; Kong, Y; Cao, J. (2017). HMGA2 plays an important role in Cr (VI)-induced autophagy. Int J Cancer 141: 986–997. 10.1002/ijc.30789.28510366
Yang, Y; Liu, H; Xiang, XH; Liu, FY. (2013). Outline of occupational chromium poisoning in China. Bull Environ Contam Toxicol 90: 742–749. 10.1007/s00128-013-0998-3.23604023
Yawets, A; Alter, A; Oron, U. (1984). Biochemical and histological anomalies in the rat hepatic tissue following administration of bichromate and nickel in ionized form. Toxicology 33: 145–155.6506083
Yazar, S; Yildirim, IY. (2018). Oxidative DNA damage in electroplaters co-exposed to chromium and nickel. Fresen Environ Bull 27: 6831–6836.
Yi, X; Xiao, F; Zhong, X; Duan, Y; Liu, K; Zhong, C. (2017). A Ca(2+) chelator ameliorates chromium (VI)-induced hepatocyte L-02 injury via down-regulation of voltage-Dependent anion channel 1 (VDAC1) expression. Environ Toxicol Pharmacol 49: 27–33. 10.1016/j.etap.2016.11.007.27898307
Yi, X; Zhang, Y; Zhong, C; Zhong, X; Xiao, F. (2016). The role of STIM1 in the Cr(vi)-induced [Ca(2+)]i increase and cell injury in L-02 hepatocytes. Metallomics 8: 1273–1282. 10.1039/c6mt00204h.27868128
Yoisungnern, T; Das, J; Choi, YJ; Parnpai, R; Kim, JH. (2015). Effect of hexavalent chromium-treated sperm on in vitro fertilization and embryo development. Toxicol Ind Health. 10.1177/0748233715579805.
Yousef, MI; El-Demerdash, FM; Kamil, KI; Elaswad, FA. (2006). Ameliorating effect of folic acid on chromium(VI)-induced changes in reproductive performance and seminal plasma biochemistry in male rabbits. Reprod Toxicol 21: 322–328. 10.1016/j.reprotox.2005.09.005.16249067
Yuan, JH. (1993). Modeling blood/plasma concentrations in dosed feed and dosed drinking water toxicology studies. Toxicol Appl Pharmacol 119: 131–141.8470117
Yuan, TH; Lian, I, eB; Tsai, KY; Chang, TK; Chiang, CT; Su, CC; Hwang, YH. (2011). Possible association between nickel and chromium and oral cancer: a case-control study in central Taiwan. Sci Total Environ 409: 1046–1052. 10.1016/j.scitotenv.2010.11.038.21195455
Yuan, WM; Lu, YQ; Wei, Z; Chen, M; He, SL; Mai, WY; Zhang, MB. (2016). An epistaxis emergency associated with multiple pollutants in elementary students. Biomed Environ Sci 29: 893–897. 10.3967/bes2016.119.28081750
Yuan, Y; Ming, Z; Gong-Hua, H; Lan, G; Lu, D; Peng, L; Feng, J; Cai-Gao, Z. (2012). Cr(VI) induces the decrease of ATP level and the increase of apoptosis rate mediated by ROS or VDAC1 in L-02 hepatocytes. Environ Toxicol Pharmacol 34: 579–587. 10.1016/j.etap.2012.06.016.22858589
Yuann, JM; Liu, KJ; Hamilton, JW; Wetterhahn, KE. (1999). In vivo effects of ascorbate and glutathione on the uptake of chromium, formation of chromium(V), chromium-DNA binding and 8-hydroxy-2'-deoxyguanosine in liver and kidney of osteogenic disorder shionogi rats following treatment with chromium(VI). Carcinogenesis 20: 1267–1275.10383900
Zecevic, A; Menard, H; Gurel, V; Hagan, E; Decaro, R; Zhitkovich, A. (2009). WRN helicase promotes repair of DNA double-strand breaks caused by aberrant mismatch repair of chromium-DNA adducts. 8: 2769–2778.
Zeiger, E; Anderson, B; Haworth, S; Lawlor, T; Mortelmans, K. (1992). Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19: 2–141. 10.1002/em.2850190603.1541260
Zendehdel, R; Shetab-Boushehri, SV; Azari, MR; Hosseini, V; Mohammadi, H. (2014). Chemometrics models for assessment of oxidative stress risk in chrome-electroplating workers. Drug Chem Toxicol 38: 1–6. 10.3109/01480545.2014.922096.24580112
Zeng, M; Xiao, F; Zhong, X; Jin, F; Guan, L; Wang, A; Liu, X; Zhong, C. (2013). Reactive oxygen species play a central role in hexavalent chromium-induced apoptosis in Hep3B cells without the functional roles of p53 and caspase-3. Cell Physiol Biochem 32: 279–290. 10.1159/000354436.23942225
Zhang, Q; Kluz, T; Salnikow, K; Costa, M. (2002). Comparison of the cytotoxicity, cellular uptake, and DNA-protein crosslinks induced by potassium chromate in lymphoblast cell lines derived from three different individuals. Biol Trace Elem Res 86: 11–22. 10.1385/BTER:86:1:11.12002656
Zhang, R; Xiang, Y; Ran, Q; Deng, X; Xiao, Y; Xiang, L; Li, Z. (2014). Involvement of calcium, reactive oxygen species, and ATP in hexavalent chromium-induced damage in red blood cells. Cell Physiol Biochem 34: 1780–1791. 10.1159/000366378.25427846
Zhang, XH; Zhang, X; Wang, XC; Jin, LF; Yang, ZP; Jiang, CX; Chen, Q; Ren, XB; Cao, JZ; Wang, Q; Zhu, YM. (2011). Chronic occupational exposure to hexavalent chromium causes DNA damage in electroplating workers. BMC Public Health 11: 224. 10.1186/1471-2458-11-224.21481275
Zhang, XH; Zhang, X; Zhang, L; Chen, Q; Yang, Z; Yu, J; Fu, H; Zhu, YM. (2012). XRCC1 Arg399Gln was associated with repair capacity for DNA damage induced by occupational chromium exposure. BMC Research Notes 5: 263. 10.1186/1756-0500-5-263.22642904
Zhang, Y; Su, Z; Hu, G; Hong, S; Long, C; Zhang, Q; Zheng, P; Wang, T; Yu, S; Yuan, F; Zhu, X; Jia, G. (2022). Lung function assessment and its association with blood chromium in a chromate exposed population. Sci Total Environ 818: 151741. 10.1016/j.scitotenv.2021.151741.34808188
Zhang, Y; Xiao, F; Liu, X; Liu, K; Zhou, X; Zhong, C. (2017). Cr(VI) induces cytotoxicity in vitro through activation of ROS-mediated endoplasmic reticulum stress and mitochondrial dysfunction via the PI3K/Akt signaling pathway. Toxicol In Vitro 41: 232–244. 10.1016/j.tiv.2017.03.003.28323103
Zhang, Y; Zhang, Y; Zhong, C; Xiao, F. (2016). Cr(VI) induces premature senescence through ROS-mediated p53 pathway in L-02 hepatocytes. Sci Rep 6(34578): 1–10. 10.1038/srep34578.28442746
Zhao, L; Song, Y; Pu, J; Guo, J; Wang, Y; Chen, Z; Chen, T; Gu, Y; Jia, G. (2014). Effects of repeated Cr(VI) intratracheal instillation on club (Clara) cells and activation of nuclear factor-kappa B pathway via oxidative stress. Toxicol Lett 231: 72–81. 10.1016/j.toxlet.2014.09.011.25240275
Zhao, M; Xu, J; Li, A; Mei, Y; Ge, X; Liu, X; Wei, L; Xu, Q. (2020). Multiple exposure pathways and urinary chromium in residents exposed to chromium. Environ Int 141: 105753. 10.1016/j.envint.2020.105753.32417613
Zheng, W; Ge, F; Wu, K; Chen, X; Li, X; Chen, Y; Lv, Y; Lian, Q; Ge, RS. (2018). In utero exposure to hexavalent chromium disrupts rat fetal testis development. Toxicol Lett 299: 201–209. 10.1016/j.toxlet.2018.10.010.30315952
Zhitkovich, A; Costa, M. (1992). A simple, sensitive assay to detect DNA-protein crosslinks in intact cells and in vivo. Carcinogenesis 13: 1485–1489. 10.1093/carcin/13.8.1485.1499101
Zhitkovich, A; Lukanova, A; Popov, T; Taioli, E; Cohen, H; Costa, M; Toniolo, P. (1996). DNA-protein crosslinks in peripheral lymphocytes of individuals exposed to hexavalent chromium compounds. Biomarkers 1: 86–93. 10.3109/13547509609088675.23888918
Zhitkovich, A; Peterson-Roth, E; Reynolds, M. (2006). Abnormal processing of chromium-DNA adducts by mismatch repair proteins activates genotoxicity of chromium(VI) [Abstract]. Toxicol Sci 90: 107–108.
Zhitkovich, A; Quievryn, G; Messer, J; Motylevich, Z. (2002). Reductive activation with cysteine represents a chromium(III)-dependent pathway in the induction of genotoxicity by carcinogenic chromium(VI). Environ Health Perspect 110 Suppl 5: 729–731.
Zhitkovich, A; Shrager, S; Messer, J. (2000). Reductive metabolism of Cr(VI) by cysteine leads to the formation of binary and ternary Cr--DNA adducts in the absence of oxidative DNA damage. Chem Res Toxicol 13: 1114–1124.11087433
Zhitkovich, A; Song, Y; Quievryn, G; Voitkun, V. (2001). Non-oxidative mechanisms are responsible for the induction of mutagenesis by reduction of Cr(VI) with cysteine: role of ternary DNA adducts in Cr(III)-dependent mutagenesis. Biochemistry 40: 549–560. 10.1021/bi0015459.11148050
Zhitkovich, A; Voitkun, V; Costa, M. (1995). Glutathione and free amino acids form stable complexes with DNA following exposure of intact mammalian cells to chromate. Carcinogenesis 16: 907–913.7728973
Zhitkovich, A; Voitkun, V; Kluz, T; Costa, M. (1998). Utilization of DNA-protein cross-links as a biomarker of chromium exposure. Environ Health Perspect 106 Suppl 4: 969–974.9703480
Zhivin, S; Laurier, D; Caër-Lorho, S; Acker, A; Guseva Canu, I. (2013). Impact of chemical exposure on cancer mortality in a French cohort of uranium processing workers. Am J Ind Med 56: 1262–1271. 10.1002/ajim.22231.24009194
Zhong, X; de Cássia da Silveira E Sá, R; Zhong, C. (2017a). Mitochondrial biogenesis in response to chromium (VI) toxicity in human liver cells. International Journal of Molecular Sciences 18. 10.3390/ijms18091877.
Zhong, X; Yi, X; da Silveira E Sá, RC; Zhang, Y; Liu, K; Xiao, F; Zhong, C. (2017b). CoQ10 Deficiency May Indicate Mitochondrial Dysfunction in Cr(VI) Toxicity. International Journal of Molecular Sciences 18. 10.3390/ijms18040816.
Zhong, X; Zeng, M; Bian, H; Zhong, C; Xiao, F. (2017c). An evaluation of the protective role of vitamin C in reactive oxygen species-induced hepatotoxicity due to hexavalent chromium in vitro and in vivo. J Occup Med Toxicol 12: 12. 10.1186/s12995-017-0161-x.28559919
Zhou, W; Yu, T; Vazin, M; Ding, J; Liu, J. (2016). Cr(3+) binding to DNA backbone phosphate and bases: Slow ligand exchange rates and metal hydrolysis. Inorg Chem 55: 8193–8200. 10.1021/acs.inorgchem.6b01357.27478904
Ziliak, ST. (2011). Matrixx v. Siracusano and Student v. Fisher. Significance 8: 131–134.
Zuo, Z; Cai, T; Li, J; Zhang, D; Yu, Y; Huang, C. (2012). Hexavalent chromium Cr(VI) up-regulates COX-2 expression through an NFκB/c-Jun/AP-1-dependent pathway. Environ Health Perspect 120: 547–553. 10.1289/ehp.1104179.22472290