# APPENDIX G SUMMARY OF PUBLIC AND EXTERNAL PEER REVIEW COMMENTS AND EPA’S

The Toxicological Review of Hexavalent Chromium was released for public comment in October 2022. Public comments on the assessment were submitted to the U.S. Environmental Protection Agency (EPA) by December 19, 2022. The Toxicological Review has also undergone a formal external peer review (https://sab.epa.gov/ords/sab/r/sab_apex/sab/advisoryactivitydetail?p18_id=2618&clear=18&session=14409207329547) by the Scientific Advisory Board (SAB) Chemical Assessment Advisory Committee (CAAC) in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). A public, external peer review meeting was held March 29‒31, 2023, which included another opportunity for public comment. The external SAB peer reviewers were tasked with providing written answers to general questions on the overall assessment approach, key conclusions, and areas of scientific controversy or uncertainty. In this Appendix, each charge question is presented with a general overview of the SAB peer reviewers’ comments, followed by the specific tiered SAB recommendations (duplicated verbatim unless otherwise indicated), with EPA’s responses given for each. In addition, a summary of the general comments made by the public commenters, as well as EPA’s responses, are arranged by charge question. Please consult the final peer review report for the full text of the panel’s comments: Peer Review Report (https://sab.epa.gov/ords/sab/f?p=114:0:14409207329547:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1121). External peer reviewers were asked to prioritize their comments to indicate their relative importance as follows. The prioritization instructions are duplicated below from the IRIS Cr(VI) charge questions to the peer reviewers, which can be found in the public EPA docket (EPA-HQ-ORD-2014-0313 (https://www.regulations.gov/docket/EPA-HQ-ORD-2014-0313)):

- Tier 1: Necessary Revisions – Use this category for any revisions you believe are necessary to adequately support and substantiate the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the Cr(VI) Toxicological Review.
- Tier 2: Suggestions – Use this category for any revisions you encourage EPA to implement to strengthen the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the Cr(VI) Toxicological Review.
- Tier 3: Future Considerations – Use this category for any advice you have for scientific exploration that might inform future work. While these recommendations are generally outside the immediate scope or needs of the Cr(VI) Toxicological Review, they could inform future reviews or research efforts.

Appendix G lists all Tier 1 recommendations and Tier 2 suggestions from the external peer reviewers organized by charge question. For Tier 3 considerations, please refer to the external peer review report linked above. Where public comments were made on topics raised by the external peer reviewers, they are noted along with the external peer review comments. All Tier 1 recommendations were implemented in this revised assessment, either through revision or addition to the peer reviewed analyses or text. Tier 2 suggestions were considered in light of the extent to which those suggestions would impact the conclusions or quantitative analyses of the assessment, consistency across committee in raising the suggestion, and the level of effort to implement. For this assessment, all Tier 2 suggestions deemed to be impactful to the toxicity value conclusions were implemented in this revised assessment. Additional public comments not raised by the peer reviewers are included in a separate section at the end of each charge question section. In most cases, the public comments have been abridged and paraphrased for brevity, both in this Appendix and in the summary document provided as a courtesy to the external peer review panel. Please see the docket (EPA-HQ-ORD-2014-0313 (https://www.regulations.gov/docket/EPA-HQ-ORD-2014-0313)) for this summary document and the full text of the submitted public comments.

External peer reviewer comments and public comments regarding requests for additions of clarifying text or editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this Appendix.

## G.1 CHARGE QUESTIONS 1 AND 2 - SYSTEMATIC REVIEW AND DOCUMENTATION

1) The Toxicological Review describes and applies a systematic review process for identifying and screening pertinent studies that is described in detail in Section 1.2.1 (Literature Search and Screening) and Appendix A (Systematic Review Protocol). Please comment on whether the literature search strategy and screening criteria for Cr(VI) are appropriate and clearly described. Please identify additional peer-reviewed studies of Cr(VI) compounds that the assessment should consider.^11^
2) The Toxicological Review describes the results of the evaluations of individual studies in Section 2.2 (Study Evaluation Results) and presents and analyzes the findings from those studies deemed informative in the relevant health effect-specific synthesis sections.
  a. Results from individual Cr(VI) studies are presented and synthesized in the health system-specific sections. Please comment on whether the presentation and analysis of study results is clear, appropriate, and effective to allow for scientifically supported syntheses of the findings across sets of studies.
  b. Please comment on whether the study confidence conclusions for the Cr(VI) studies are scientifically justified, giving appropriate consideration to important methodological features of the assessed outcomes. Please specify any study confidence conclusions that are not justified and explain any alternative study evaluation decisions.

### G.1.1 External Peer Reviewer Comments on Systematic Review and Documentation

For charge question 1, “in general, the literature search strategy is clearly described.” Overall, the panel “considered EPA’s approach for gathering all the information in the draft IRIS assessment to be rigorous,” and “in general, the screening criteria are appropriate and clearly described.” However, the report noted that “the panel identified a number of areas where the bases for EPA’s choices of scientific literature were not transparent, and clarifications are recommended. For example, there is some lack of transparency and clarity regarding the decisions to include and exclude certain literature. This makes it more difficult for external reviewers to replicate EPA’s strategy, and to fully understand why some studies were not cited as important especially regarding mode of action (MOA) and mechanisms.” The panel pointed to a lack of transparency in the literature flow diagram, where the stage of screening and rationale for exclusions are not noted and provided a list of studies thought to have been excluded without rationale. The panel also suggested that EPA use other MOA framework publications, in addition to EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), to help provide a comparison for the two most relevant hypothesized MOAs for Cr(VI)-induced cancer and provided a list of these publications in the report Appendix A. However, it was recognized by the panel that “the Cr(VI) literature is vast, and studies logged into HERO and/or Health Assessment Workspace Collaborative (HAWC) databases may not necessarily be cited in the final IRIS assessment if they did not meaningfully contribute or alter the conclusions made by the EPA.”

For charge question 2, the panel found that “the sections in the draft IRIS assessment, where the analysis of studies was presented, were generally clear and effective,” and “overall, the study confidence conclusions appear scientifically justified and clearly described, considering important study attributes such as methodological features of the assessed outcomes.” However, the panel also commented that “the study confidence conclusions for epidemiological studies are not always consistent when deficiencies in the exposure or health outcome domains are noted,” pointing to study limitations apparently leading to low confidence ratings for some studies and uninformative for others, and questioned (in charge question 1) why supplemental studies did not receive the same level of scrutiny (i.e., conducting study evaluations) as the studies meeting PECO criteria. The report did not recommend Tier 1 revisions for charge questions 1 and 2 but had several Tier 2 suggested revisions that are described below.

#### G.1.1.1 Tier 1 Recommendations

There were no Tier 1 recommendations.

#### G.1.1.2 Tier 2 Suggestions

SAB Comment: The EPA should provide more clarity and transparency relative to the criteria for inclusion and exclusion of specific studies and tabulate the excluded papers (especially those listed below under “Other Studies for inclusion” section) in an appendix so that the reader of the draft IRIS assessment can understand the types of studies that were eliminated from consideration and why.

EPA Response: The assessment PECO (Populations, Exposures, Comparators, and Outcomes) criteria are used to identify the studies most likely to be informative to assessment conclusions, including the derivation of toxicity values. As described in the IRIS Handbook (U.S. EPA, 2022b) (p. 2–22), studies are “excluded” if they do not meet at least one type of evidence in each PECO component. Literature screening using the PECO criteria is conducted at the title and abstract (TIAB) and full-text levels (for useful examples, please see Figures 2-2 and 2-3 in the IRIS Handbook). At the TIAB stage, a single screened-out study may have multiple reasons for exclusion that would be unwieldy to document, particularly at the TIAB level where screening may be conducted for thousands of studies. Therefore, the IRIS process does not require screeners to annotate the rationale for excluding studies at the TIAB level (U.S. EPA, 2022b) (p. 2–23). This is consistent with broader systematic review practices for TIAB screening, especially for projects with many records. For the Cr(VI) assessment, there were over 14,000 studies that were excluded entirely for one or more PECO criteria not met. Most of these studies were not related to Cr(VI) toxicology, but other topics such as analytical methods, land remediation, or industrial uses of Cr(VI) compounds. These studies are categorized as “other Cr compounds” or “other not pertinent” in the HERO project page for Chromium VI (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2233).

For the second round of screening studies at the full-text level, the current IRIS process for newly initiated projects suggests that the rationales for excluding studies should be documented using specific exclusion tags (U.S. EPA, 2022b) (p. 2–24). However, aside from a few exceptions [i.e., the specific literature search conducted for the meta-analysis of inhalation studies reporting gastrointestinal effects (see Appendix C.3.1.2, Table C-44) and the selection of inhalation studies considered for deriving the RfC (see Appendix D.4, Table D-16)], individual rationales were not given for studies excluded at the full-text screening stage. The process to update the 1998 Cr(VI) assessment has been underway since 2008, well before the systematic review procedures described in the IRIS Handbook were in place. As described in the protocol (see Appendix A), the 2014 Cr(VI) preliminary materials (U.S. EPA, 2014b, c) included an extensive scoping and problem formulation process that helped identify studies eligible for study evaluation that were made available for public comment. In 2019, following a further refinement of systematic review procedures within the IRIS Program, the Cr(VI) protocol was released. The protocol summarized the 2014 preliminary materials and PECO criteria. While the literature screening software used in 2014 did not permit tagging of screening level exclusions and rationales, it was determined that the level of effort required to rescreen and tag >20,000 records studies solely for the purpose of creating high-level exclusion tags was not warranted. In addition, the studies identified in 2014 were reviewed and commented on by the public and discussed in two public meetings. Additional clarifying text to this effect has been added to the protocol (see Section 4.3).

Many studies not meeting PECO criteria are not “excluded” from the assessment but are categorized as “potentially relevant supplemental material” and tagged to both describe why they did not meet PECO (e.g., “dermal studies,” “injection/intratracheal studies,” “acute exposures”) and to provide easy retrieval later (if needed to address a specific assessment issue). These tagged studies can be found in the HERO project page for Cr(VI) (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2233). Approximately 4,000 studies screened for Cr(VI) that did not meet all PECO criteria were considered to have potentially relevant supplemental information. The major tagging categories are outlined in Table 3-2 and in Section 4 of the protocol. Tabular inventories and brief overviews of the prioritized supplemental studies are available in Appendix C.

EPA created Table G-1 (see below) that focuses on the specific supplemental studies presumed to be excluded that were highlighted by SAB. Unless otherwise noted, all studies listed in this table were already tagged in the Cr(VI) HERO library at the time the draft Cr(VI) assessment was released for public comment. Studies not previously identified were tagged “identified by peer reviewers.” Relevant HERO tags are listed, and (if applicable) where the reference is cited in the documents. This tabulation was only performed on studies listed under “Other Studies for inclusion” section of the SAB comments and can be used as a representative sampling of studies that are supplemental but do not meet PECO.

Many supplemental references (particularly older ones) were not cited in the assessment in favor of newer research. In general, review articles and book chapters are not included in IRIS assessments if they do not report original findings, although they can be used to identify references that may have been missed by literature searches. In other instances, instead of citing all references that pertain to well-studied topic areas, some exceptions are made for citing reviews that cover broadly accepted biological concepts. For example, the assessment cites reviews relevant to Cr(VI)-induced oxidative stress in Section 3.2.3.4.

Reviews were also cited in lieu of original reports of experimental studies supporting the genotoxic effects of Cr(VI) in vitro. Rather than systematically reviewing each study in the broad and dense literature base that supports the genotoxicity of Cr(VI), the assessment protocol accepted the well-established genotoxicity of Cr(VI) in vitro in animal cell lines and bacterial systems and prioritized the review of evidence that studied genetic effects in humans (in vitro or in vivo), or in animal models in vivo following exposure scenarios of prioritized relevance (inhalation or ingestion). (Note that this is a separate issue from the Tier 1 comment on Charge Question 6a regarding the review of Cr-DNA interactions leading to genotoxicity; please see Section G.5 for more information on these studies.) As noted by SAB, the literature is vast, and all studies in the HERO database may not necessarily be cited in the final assessment.

In response to the SAB comments on the potential inclusion of recently published human studies (the “Other Studies for inclusion” section, found in Appendix B of the SAB report), please see Table G-2, below. Many studies in this list did not meet PECO criteria; the rationale for PECO exclusion is provided for each. Studies that are contained in the HERO database or cited in the document are noted, and as described above, newly identified studies were also tagged “identified by peer reviewers.”

Table G-1 Tagging overview of supplemental studies identified by the Science Advisory Board

Reference | HERO tag | Notes
Cr(VI) MOA studies
Bhat et al. (2020) | Review^a^
Chappell et al. (2021) | Review^a^
Chappell et al. (2022) | Mechanistic | Inventoried in mechanistic evidence; cited in external peer review draft, Section 3.2.3.4 (cancer MOA).
Haney (2015a) | Other agency assessments | Considered to be a review (no original data); cross-referenced with the TCEQ assessment TCEQ (2016).
Haney (2015c) | Other agency assessments | Considered to be a review (no original data); cross-referenced with the TCEQ assessment TCEQ (2016).
Haney (2015b) | Review^a^
Thompson et al. (2021) | Review^a^
Costa laboratory
Sen et al. (1987) | Mechanistic | In vitro study of chromosomal aberrations in Chinese hamster ovary cells and in C3H10T1/2 cells.^b^ Added to Appendix Table C-54.
Sugiyama et al. (1988) | Mechanistic | In vitro study of DNA lesions in Chinese hamster V-79 cells.^b^
Miller and Costa (1988) | Mechanistic | In vitro study of DNA-protein complexes in Chinese hamster ovary cells.^b^
Miller and Costa (1989) | Mechanistic | Deprioritized during screening as an assay development/validation study that does not provide supporting information for mechanisms.
Miller et al. (1991) | Mechanistic | In vitro study of DNA-protein complexes in Chinese hamster ovary cells.^b^
Coogan et al. (1991b) | ADME | Cited in external peer review supplemental draft (see Appendix C.1.6, Tables C-23 and C-24).
Costa (1991) | Mechanistic | In vitro study of DNA-protein complexes in Chinese hamster ovary cells.^b^
Sugiyama et al. (1991) | Mechanistic | In vitro study of the effects of Vitamin E on mutations induced by Cr(VI) in Chinese hamster V-79 cells.^b^
Coogan et al. (1991a) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.2.3, Table C-34, and Appendix C.3.2.1, Table C-46).
Chen et al. (1991) | Mechanistic | Deprioritized during screening as an assay development/validation study that does not provide supporting information for mechanisms.
Zhitkovich and Costa (1992) | Mechanistic | Deprioritized during screening as an assay development/validation study that does not provide supporting information for mechanisms.
Lin et al. (1992) | Mechanistic | In vitro study of Cr-induced DNA-protein crosslinks and detection methods in Chinese hamster ovary cells.^b^
Sugiyama et al. (1992) | Mechanistic | In vitro study of the effects of Vitamin B2 on mutations induced by Cr(VI) in Chinese hamster V-79 cells.^b^
Salnikow et al. (1992) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.3.2.1, Table C-46).
Kargacin et al. (1993) | ADME | Cited in external peer review supplemental draft (see Appendix C.1.2, Table C-5, and C.1.6, Table C-23). Data were fully extracted and presented in appendix.
Toniolo et al. (1993) | N/A | Not captured in Cr(VI) literature search; study added to the Cr(VI) project in HERO and tagged “mechanistic.” Not considered for genotoxicity synthesis; as described in protocol, occupational exposures to welding fume other than stainless steel are likely to have lower and more variable exposure to Cr(VI).
Costa (1993) | Mechanistic | Deprioritized during screening as an assay development/validation study that does not provide supporting information for mechanisms.
Zhitkovich et al. (1995) | Mechanistic | In vitro study of Cr-DNA-glutathione complexes in Chinese hamster ovary cells; added to Table C-46 in Appendix C.3.2.1.
Taioli et al. (1995) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.3.2.2, Table C-49).
Zhitkovich et al. (1996) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.3.2.2, Table C-49).
Costa et al. (1996) | Mechanistic | Deprioritized during screening because these data were originally reported in Costa et al. (1993), which is cited in the external peer review supplemental draft (see Appendix C.3.2.2, Table C-49).
Lukanova et al. (1996) | ADME | Cited in external peer review supplemental draft (see Appendix C.1.6, Table C-26).
Costa (1997) | Review^a^
Voitkun et al. (1998) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.3.2, Table C-46) and in DNA reactivity analysis now located in the main draft (see Section 3.2.3.4).
Zhitkovich et al. (1998) | Review^a^ | Deprioritized during screening; paper is based on a symposium overview presentation.
Cohen and Costa (1992) | Review^a^ | Book chapter (no original data).
Cohen and Costa (2000) | Review^a^ | Book chapter (no original data).
Sutherland et al. (2000) | ADME | Cited in external peer review supplemental draft (see Appendix C.1.6, Table C-23).
Zhang et al. (2002) | Mechanistic | Cited in external peer review supplemental draft (see Appendix C.3.2, Table C-53).
Costa et al. (2002b) | Review^a^ | Book chapter (no original data).
Costa et al. (2002a) | N/A | Study was contained in prior archived Cr(VI) assessment library; added to current Cr(VI) project and updated tag as “review.”
Davidson et al. (2004) | Mechanistic | Cited in external peer review draft (see Section 3.2.3.4).
Costa and Klein (2006) | Review^a^
Arakawa et al. (2006) | Mechanistic | In vitro study sequencing Cr-induced mutations in p53 gene of plasmid DNA^b^; previously deprioritized, now added to “Signature mutations” in the synthesis of animal genotoxicity evidence in Section 3.2.3.3.
Ke and Costa (2007) | N/A | Study added to HERO. Book chapter (no original data; tagged as “review”) that focuses on Cr(III) (tagged as “other Cr compounds”).
Uddin et al. (2007) | Mechanistic | Cited in external peer review draft (see Section 3.2.3.4).
Langård and Costa (2007) | N/A | Study added to HERO. Book chapter (no original data); tagged as “review.”
Qu et al. (2008) | Exposure assessments | Cited in external peer review supplemental draft (see Appendix C.1.2 and C.3.5, Table C-65).
Sun et al. (2009) | Mechanistic | In vitro study of Cr(VI)-induced epigenetic effects in human lung cell line; added to Appendix C.3.2.4, Table C-55.
Wu et al. (2012) | Mechanistic | Cited in external peer review supplemental draft Table C-62 as a gene expression study not included in review of toxicogenomic data due to limited scope (antioxidant pretreatment study) (see Appendix C.3.4).
Clancy et al. (2012) | Mechanistic | Cited in external peer review supplemental draft Table C-62 as a gene expression study included and evaluated in the review of toxicogenomic data (see Appendix C.3.4).
Desmarais and Costa (2019) | Review^a^
Chen et al. (2019a) | Review^a^
Sun and M (2021) | N/A | Study added to HERO. Not captured in Cr(VI) literature search update. Book chapter (no original data); tagged “review.”

a Reviews are not typically included in IRIS assessments unless they report original data or are used to illustrate a well-characterized biological concept.

b As described in Section 3.2.3.3 of the assessment, studies of genotoxicity endpoints in animal cells in vitro or in bacterial systems are not prioritized for individual citation in the assessment. These studies are largely positive and therefore priority was given to studies of the mechanistic underpinnings of this genotoxicity (see Section 3.2.3.4, DNA reactivity) and to mutation endpoint studies in exposed humans, in human cells in vitro, or in animals in vivo exposed via inhalation or ingestion.

Table G-2 Overview of recent human studies identified by the Science Advisory Board

Citation | Notes
Behrens et al. (2023) | Study added to HERO. This study was published after release of the external review draft. While it meets PECO, it was not incorporated into the assessment analysis of studies that could inform estimation of the exposure-response function that could be used to derive an IUR because it was judged not to have a material impact on assessment conclusions (i.e., identified hazards or toxicity values). The assigned exposure concentrations were for job categories and did not necessarily correspond to a particular worker’s job history. Also, the assigned exposure concentrations were largely based on job and country specific measurements of Total Cr in air. There was very little contrast between the lowest and highest exposure levels, which may be a reflection of the identified potential sources of bias and uncertainty in the exposure measurements. For these reasons, the study would be deficient or lower for the exposure measurement domain and unlikely to have a substantial impact on the assessment conclusions. There was also significant exposure to asbestos [Table 3 of Peters et al. (2016)] in the SYNERGY cohort, and there was significant (for men only) adjusted OR for asbestos (about 1.3 for men and 1.1 for women) [Olsson et al. (2017)], but exposure to asbestos was not accounted in Behrens et al. (2023). Discussion of this article and its findings of increased lung cancer risks even among never smokers has been added to the cancer dose-response section on uncertainty due to potential effect modification (see Section 4.4.5.7). Also see response under Charge Question 6.
Gu et al. (2022) | Study added to HERO. Study does not meet PECO, study is of trivalent chromium, and neurological effects are out of scope; tagged in supplemental materials as “other Cr compounds” and “other not pertinent.”
Hossini et al. (2022) | Study added to HERO. Study does not meet PECO; tagged in supplemental materials as review article.
Hu et al. (2022) | Tagged in supplemental materials as “related to included study.” Study is cross-referenced with Zhang et al. (2022), which is the same cohort. Zhang et al. (2022) included in the noncancer lower respiratory synthesis. When multiple studies originate from the same cohort, all studies are utilized for their information, but only one representative study is typically cited as “included.”
Leese et al. (2023) | Study added to HERO. Study does not meet PECO; tagged in supplemental materials as exposure assessment. EPA is aware of the HBM4EU biomonitoring study and has included them as supplementary material when encountered in literature searches. For example, Santonen et al. (2022) and Viegas et al. (2022), two HBM4EU studies, are tagged mechanistic. Other HBM4EU studies are tagged as review articles, or as excluded not pertinent (if they are proof-of concept papers, discussions on future research directions, etc.).
Mahiout et al. (2022) | Study added to HERO. Study does not meet PECO: 1) No direct air measurements (conversions based on urinary total Cr), and 2) no outcome data. Tagged as excluded.
Muller et al. (2020) | Tagged in supplemental materials as mechanistic. This occupational study includes the detection of micronuclei in exposed workers and therefore meets the prioritization criteria for study evaluation in HAWC. This evaluation has been conducted (see HAWC) and the study has been added to the human genotoxicity evidence synthesis in Section 3.2.3.3.
Ndaw et al. (2022) | Study added to HERO. HBM4EU paper. Study does not meet PECO; tagged in supplemental materials as exposure assessment.
Proctor et al. (2021) | Tagged in supplemental materials as review article.
Santonen et al. (2023) | Study added to HERO. Study does not meet PECO, is policy discussion related to the HBM4EU study; tagged in supplemental materials as review article.
Santonen et al. (2022) | Tagged in supplemental materials as mechanistic and exposure assessment. HBM4EU paper. Cited in external peer review supplemental draft in Table C-26 (see Appendix C.1.6) identifying human biomonitoring studies.
Speer et al. (2022) | Tagged in supplemental materials as mechanistic. This study was deprioritized due to use of a form of Cr(VI), zinc chromate, that is not included in this assessment.
Viegas et al. (2022) | Tagged in supplemental materials as mechanistic and exposure assessment. HBM4EU paper. Cited in external peer review supplemental draft in Table C-26 (see Appendix C.1.6) identifying human biomonitoring studies.
Wang et al. (2022) | Tagged in supplemental materials as ADME and mechanistic. Cited in external peer review draft (see Section 3.1.2) and supplemental draft (see Appendix C.1.5, C.1.6, Table C-24).
Xia et al. (2022) | Tagged in supplemental materials as mechanistic. Added to Section 3.2.1.3 (respiratory effects, cytotoxicity evidence) and to Appendix Table C-48 in C.3.2.2.
Zhang et al. (2022) | This study meets PECO and was synthesized with the human evidence in the noncancer respiratory section in the external peer review draft (released in October 2022).

SAB Comment: The EPA should clarify that not all studies in the HERO and HAWC databases are cited in the report, and that the focus was on citing the subset of the literature that drove EPA’s conclusions.

EPA Response: A statement to this effect was added to the assessment in Section 2.1.

SAB Comment: The EPA should add publications in supplemental materials regarding non-Cr(VI) MOA frameworks and drinking water criteria.

EPA Response: Regarding drinking water criteria studies, more recent publications regarding drinking water criteria have been added to Appendix Table B-3. Regarding MOA frameworks, the U.S. EPA follows its own MOA guidance within EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a). This framework for the hazard identification, dose-response, and hazard characterization of carcinogenic agents was created by the U.S. EPA in concert with the IPCS MOA guidelines. The MOA frameworks suggested by the SAB (which can be found in Appendix A of the SAB Report) have approaches that are generally consistent with the EPA cancer guidelines; therefore, the use of other frameworks would have no impact on the MOA conclusions. (The use of the IPCS framework is further addressed in the responses to public comments under Charge Question 6 in Section G.5.2.)

SAB Comment: The EPA should provide more clarity and transparency relative to the basis for the differing degree of scrutiny applied to the supporting studies.

EPA Response: As noted above, approximately 4,000 studies in the literature base for Cr(VI) were considered to have potentially relevant supplemental information during screening despite not meeting all PECO criteria. As described in the IRIS Handbook (U.S. EPA, 2022b), these studies do not typically undergo the same evaluations as studies meeting PECO criteria unless specifically noted in the assessment protocol. This includes ADME and PBPK papers, which were screened and evaluated according to the Umbrella Quality Assurance Project Plan (QAPP) for PBPK Models (U.S. EPA, 2018). For mechanistic studies, due to the large number of supplemental studies identified for Cr(VI), a prioritization strategy was applied to focus the analysis on the evidence most likely to inform MOA decisions regarding the mutagenic potential of exposures to Cr(VI) in humans, which was identified as the most challenging and contentious question in the cancer assessment. Mechanistic studies were prioritized for further consideration if they were relevant to understanding the genotoxic potential of Cr(VI) when ingested or inhaled. These included studies measuring genotoxicity biomarkers in humans exposed to Cr(VI), genotoxicity studies conducted in mammals exposed to Cr(VI), or in vitro studies involving human primary cells or cell lines. Of these, studies were further prioritized for study evaluation for reporting, risk of bias, and sensitivity if they reported on measures of mutation (i.e., gene mutation, chromosomal aberrations, and micronuclei) in exposed humans or in animals in vivo. This strategy is described in Section 3.2.3.3 of the assessment and in Section 5.3 of the assessment protocol; additional clarifying text has been added to the protocol.

SAB Comment: Figure 1. [EPA note: now Figure 4-1] Literature search flow diagram for Cr(VI) (p. 27 of the Systematic Review Protocol for the Hexavalent Chromium Assessment (USEPA, 2022) draft IRIS assessment) presents a nice flow chart according to Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) guidelines; but the “potentially relevant” categories don’t seem to align with the categories in Table 6 [EPA note: now Table 3-2] of the Systematic Review Protocol for the Hexavalent Chromium Assessment (USEPA, 2022).

EPA Response: Table 3-2 in the protocol, as well as the screening description of the tagging structure used in the Cr(VI) assessment literature search updates (see Section 4.3) and represented in the HERO project page for Cr(VI) (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2233), has been updated to clarify how these categories were used during screening for the Cr(VI) assessment. The literature flow diagram, found in both the assessment (see Figure 2-1) and the protocol (see Figure 4-1), has also been updated to correctly match these terms and provide current numbers for the literature tagged in each category that reflect literature identified in the peer review report.

SAB Comment: EPA should present the health effects studies in Figure 1 [EPA note: now Figure 4-1] categorized by health outcome (i.e., include information from Tables 7 and 8 [EPA note: now Tables 5-1 and 5-2] in Figure 1 of the Systematic Review Protocol for the Hexavalent Chromium Assessment (USEPA, 2022)).

EPA Response: EPA appreciates this suggestion and will consider it for new assessments. However, for the Cr(VI) assessment these outcomes can be quickly accessed in two places: (1) for human and animal studies, the tables providing a summary of the overall confidence classification for each study also provides the outcomes evaluated, because study evaluation is specific to each outcome reported in a study; and (2) the subcategorization of mechanistic studies can be found in an interactive tag-tree diagram in the HAWC database, here: https://hawc.epa.gov/lit/assessment/100500006/references/visualization/.

SAB Comment: Table 12 [EPA note: now Table 6-3] of the Systematic Review Protocol for the Hexavalent Chromium Assessment (USEPA, 2022) is very informative as a summary of key elements to be considered in epidemiological studies, but there is no similar table for animal studies. EPA should consider adding a table with key elements to be considered for animal studies.

EPA Response: The Cr(VI) assessment protocol was released in 2019, prior to the release of the first draft of the IRIS Handbook in 2020 (U.S. EPA, 2020b). As a result, several elements describing the systematic review procedures being implemented in the IRIS process, including study evaluations, were included in protocols released at the time because these were not yet available elsewhere; these were general procedures not specific to Cr(VI). Table 6-3 of the Cr(VI) assessment protocol is now obsolete, as the types of information described here were either redundant with the prompting questions described in Table 6-2 of the protocol [this table is presented in parts in Section 4.2 of the current IRIS Handbook (U.S. EPA, 2022b)], or are more clearly articulated in the text introducing each domain in the Handbook (see Section 4.2). The IRIS Handbook also contains full descriptions and tables of the evaluation considerations for experimental animal studies (see Section 4.4) and in vitro studies (see Section 4.5.3). Thus, current and future IRIS protocols no longer include Table 6-3.

SAB Comment: The EPA should review their selection and discussion of epidemiologic studies for consistency in approach when significant deficiencies in exposure or health outcome assessment are noted. The selection of epidemiologic studies should maintain similar standards for different health outcomes to remove inconsistency. The designation of “low confidence” or “uninformative” needs to be more specific in the criteria used.

EPA Response: With respect to specifying why studies might be low confidence or uninformative, the assessment syntheses of human and animal evidence for each health effect evaluated begin with a summary of the study evaluation findings for the studies that met PECO; the complete study evaluations are available in the HAWC database (https://hawc.epa.gov/assessment/499/). Summary tables of the overall confidence classification for each evaluated study outcome, along with a link to HAWC for a more detailed table of the same findings, are also presented in these sections. Because this detailed information is available elsewhere, these sections only provide brief descriptions of the study evaluation findings, including why some studies may have been found to be uninformative. This rating is reserved for studies that contain flaws (reflected in “critically deficient” ratings for one or more domains) that are so serious that their results are uninterpretable and are not considered again in the assessment process; definitions for each study confidence rating are provided in the IRIS Handbook (U.S. EPA, 2022b). In response to the suggestion, EPA reviewed Sections 3.2.1.1 and 3.2.9.1 to more clearly explain why studies were found to be uninformative.

SAB Comment: For increased transparency and ease of reference, the EPA should consider adding the figure summaries to the main draft IRIS assessment in addition to appearing in HAWC, which is more difficult to navigate than the draft IRIS assessment itself.

EPA Response: Study summary evaluation judgments are presented in summary tables in each section with links to the complete study evaluation HAWC “heatmap” figures that include individual domain ratings and links to the full rationale for each domain rating and overall judgments for the human and animal evidence for each health effect (https://hawc.epa.gov/assessment/499/). A similar approach is taken for data display figures.

### G.1.2 Public Comments on Systematic Review and Documentation

Public Comment: Several comments were received that were related to EPA’s responsiveness to recommendations put forth by the National Academies of Science, Engineering, and Medicine (NASEM) 2022 Review of U.S. EPA's ORD Staff Handbook for Developing IRIS Assessments. One commenter generally supported EPA’s systematic review approach but noted that the protocol is largely consistent with the 2020 draft ORD Staff Handbook for Developing IRIS Assessments and does not address the 2022 NASEM recommendations. Several related comments follow.

EPA Response: This assessment primarily follows the methodology described in the draft IRIS Handbook (U.S. EPA, 2020b), which was revised and released in 2022 (U.S. EPA, 2022b) following public peer review by National Academies of Sciences, Engineering, and Medicine (NASEM) (NASEM, 2021). Systematic review procedures implemented by IRIS Program and the development of the Cr(VI) assessment were on parallel timeframes for a number of years. When the IRIS Handbook was revised in 2022 (U.S. EPA, 2022b) to incorporate updates to assessment methodology as recommended in a report by the NASEM on the draft IRIS Handbook (U.S. EPA, 2020b), most aspects of the assessment were already underway using methods included in the draft Handbook (i.e., literature search, screening, study evaluation, evidence synthesis and integration) that were described in the Cr(VI) assessment protocol (U.S. EPA, 2019b). EPA considered the revisions made to the Handbook in response to the NASEM report and concluded that the changes would not fundamentally impact the previously initiated literature search, screening, overall study evaluation ratings, evidence synthesis judgments, or overall evidence integration conclusions. Text has been added to Section 1.2 to describe this decision.

Public Comment: One commenter pointed out that the release of the final protocol after the assessment was already conducted is contrary to accepted systematic review procedures.

EPA Response: Although the IRIS Program now releases protocols earlier in Step 1 of the IRIS Process than was done for Cr(VI), a Cr(VI) protocol was developed and released in 2019 (U.S. EPA, 2019b) to aid in the transparency of assessment methods and to better align the assessment with the updated systematic review processes being utilized in IRIS after 2017. As described above, the 2019 protocol summarized the processes described in the 2014 preliminary materials and included the identification of PECO criteria that summarized and reframed the selection criteria used in 2014. Although it is acknowledged that this is an atypical sequence for systematic review, it allowed an additional opportunity for the public to comment on the updated procedures, which resulted in revisions to the Cr(VI) assessment methods compared with the 2014 publicly released assessment materials.

Public Comment: One commenter noted that the documentation of protocol updates was insufficient for following the changes made.

EPA Response: Additional clarifications have been made to the protocol (see Appendix A) regarding updates made in the systematic review procedures implemented in the draft assessment since the protocol was first released in 2019, including expanded details on protocol updates made when the draft Cr(VI) assessment was released in October 2022. These revisions are itemized in Section 12 of the protocol, “Protocol History.”

Public Comment: One commenter pointed out that the consideration of sensitivity and reporting quality in the study evaluations for risk of bias had not been updated to be responsive to the NASEM review of the IRIS Handbook.

EPA Response: Although the refinements recommended by NASEM (NASEM, 2021) and reflected in the final IRIS Handbook are generally aimed at clarifying the IRIS study evaluation procedures for assessing sensitivity and for harmonizing reporting quality ascertainment methods between human and animal studies, it was determined by the assessment team that these minor adjustments would not result in changes to the overall study evaluation judgments, and that revising every study evaluation would yield only immaterial changes.

Public Comment: Another comment noted that the exclusion of uninformative studies is not responsive to the NASEM review of the IRIS Handbook.

EPA Response: To clarify, uninformative studies were not excluded from the assessment and underwent study evaluation if they met PECO criteria. As described above, the rating of uninformative is reserved for studies that contain flaws (reflected in “critically deficient” ratings for one or more domains) that are so serious that their results are uninterpretable and are not considered again in the assessment process; definitions for each study confidence rating are provided in the IRIS Handbook (U.S. EPA, 2022b). It is acknowledged that critical deficiencies can also result from developing PECO screening criteria that are overly broad; for future assessments, the 2022 IRIS Handbook (U.S. EPA, 2022b) outlines a strategy for identifying predetermined deficiencies that can be used during literature screening to exclude studies that would otherwise be found uninformative later (“Other exclusions based on full-text content,” p. 2–24).

Public Comment: One commenter expressed concern that ‘low confidence’ studies were either excluded or under-utilized in the development of health effect conclusions, explaining that the rating of studies as ‘low confidence’ should not automatically result in a classification of ‘slight’ evidence when there are multiple studies supporting a hazard conclusion across different laboratories, species, endpoints, and routes of exposure.

EPA Response: As noted in the protocol, overall study confidence classifications are determined based on reviewer judgments across multiple evaluation domains and include consideration of the likely impact the noted deficiencies in bias and sensitivity, or inadequate reporting, have on the results. Studies rated as low confidence are not excluded from the synthesis of effects. A rating of low confidence does not automatically result in a synthesis judgment of slight evidence; as described in the IRIS Handbook (U.S. EPA, 2022b), slight may also describe evidence consisting of high or medium confidence studies that have unexplained inconsistency or lack additional studies to confirm their findings. The synthesis judgments in the Cr(VI) assessment for hepatic and immune effects in animals have been reviewed and edited for clarity where appropriate to emphasize the rationale for the judgment of slight.

Public Comment: Two commenters presented opposite opinions related to source of funding or conflicts of interest and risk of bias. Citing the National Academy of Sciences (NAS) 2014 Review of EPA’s Integrated Risk Information System (IRIS) Process, one commenter recommends that funding sources should be considered in the risk-of-bias, although this does not mean the exclusion of industry-sponsored studies. Another commenter stated that EPA systematically dismissed data collected and funded by industry as though the source of funding inherently made the data suspect.

EPA Response: EPA neither excludes studies nor data on the basis of study sponsorship nor neglects funding source during risk-of-bias characterization. Funding sources and reporting of conflict of interest are not considered during study identification or evaluation but are noted in the HAWC database and may be considered during evidence synthesis in specific contexts, e.g., “clear conflicts of interest related to funding source can be considered as a factor to explain apparent inconsistency” during evidence synthesis judgments [IRIS Handbook, p. 6–8 (U.S. EPA, 2022b)]. However, EPA will continue to monitor the development of tools to operationalize the consideration of potential conflicts of interest during study evaluation.

Public Comment: One commenter asked that the distinction between evidence synthesis and evidence integration be better clarified as requested by the NASEM review of the IRIS Handbook.

EPA Response: The approaches implemented for evidence synthesis and integration in the Cr(VI) assessment are based on those published in the 2020 Handbook (U.S. EPA, 2020b). After receiving the NASEM peer review comments on the IRIS Handbook in 2021 (NASEM, 2021), several refinements were made to make the processes of evidence synthesis and evidence integration more distinct and transparent, but these methods were not complete when the Cr(VI) public comment draft was being prepared for release. The assessment team determined that although the refinements improved the transparency of reaching hazard conclusions, they would not result in different conclusions, and were not implemented for the Cr(IV) assessment. However, the three animal hazard synthesis judgments given as examples of unsupported decisions (hepatic, immune and male reproductive effects) have been reviewed and edited if needed to clarify the justifications given.

Public Comment: One commenter stated that the literature search strategy and screening criteria implemented by EPA did not fully capture MOA analyses. The commenter stated that updating screening methods related to MOA without updating the PECO was inconsistent with systematic review methods, and that publications synthesizing information on MOA were not captured. This commenter also did not believe the EPA provided rationale for its review methodology for mechanistic studies and stated that the process for selecting and reviewing mechanistic studies was not transparent or systematic.

EPA Response: IRIS assessments, including the Cr(VI) assessment, conduct independent analyses of original data and do not include outside analyses or reviews unless specifically noted in the assessment and/or protocol. Reviews and studies with no primary data are considered supplemental materials and are tagged accordingly in HERO. The systematic methods used to identify and prioritize studies informative to MOA analyses are described in Section 3.2.3.3 of the assessment, Appendix C.3.2.2, and the assessment protocol. Screening methods and conclusions for the cancer MOA analyses were supported by a majority of the external peer review committee, and EPA has addressed Tier 1 and Tier 2 committee comments related to this topic to improve transparency.

Regarding MOA frameworks, the US EPA follows its own MOA guidance within EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a). This framework for the hazard identification, dose-response, and hazard characterization of carcinogenic agents was created by the US EPA in concert with the IPCS MOA guidelines. Please see the similar peer-reviewer comment addressed in Appendix G.1.1 above.

Public Comment: One commenter stated that “the data quality visualizations available through EPA’s HAWC referenced by the draft toxicological review illustrate EPA’s reliance on studies that almost ubiquitously are ‘low-confidence’ with respect to carcinogenicity via oral exposure.” The commenter also stated that “HAWC visualizations with regard to Cr(VI) mechanistic studies were either not prepared or are not available to the public.”

EPA Response: The animal studies considered for the evaluation of the carcinogenic effects of ingested Cr(VI) were all high confidence (Thompson et al., 2011b; 2012c; NTP, 2007f, 2008); for more detail, please see HAWC. Besides the studies that met PECO criteria, study evaluations were also performed in HAWC for mechanistic studies that were in vivo studies reporting mutagenicity endpoints prioritized for analysis; see Section 3.2.3.3 of the assessment and Appendix C.3.2.2. for more detail. The visualizations can be found in HAWC here.

Public Comment: Several public comments were received on the study evaluation criteria used to evaluate in vivo mutagenicity studies in animals for reporting, risk of bias, and sensitivity. These comments are addressed under Charge Question 6 (see Appendix G.5.2).

## G.2 CHARGE QUESTION 3 - NONCANCER HAZARD IDENTIFICATION AND TOXICITY VALUE DERIVATION

3) For each health effect considered in the assessment and outlined below, please comment on whether the available data have been clearly and appropriately synthesized to describe the strengths and limitations and to support the conclusions presented. For each, please also comment on whether the weight-of-evidence decisions for hazard identification have been clearly described and scientifically justified, and appropriately consider health effects in susceptible subpopulations or lifestages (e.g., children) to the extent possible, given the available data. In addition, please separately comment on whether the dose-response decisions are transparent and scientifically justified, including study selection for dose-response analyses; point of departure (POD) estimates, including modeling choices and assumptions, and dosimetric adjustments; selection of uncertainty factors and derivation of candidate values; selection of organ/system-specific RfDs/RfCs; and confidence in the calculated values.
  a. Gastrointestinal (noncancer)
    i) The evidence indicates that oral exposure to Cr(VI) likely causes GI tract toxicity in humans given sufficient exposure conditions.^12^ This conclusion is primarily based on robust studies in rodents that found Cr(VI) causes non-neoplastic effects in the GI tract.
    ii) A POD from NTP (2008), a 2-year drinking water bioassay in rodents, was selected to calculate an organ/system-specific RfD of 9 × 10^−4^ mg/kg-day based on diffuse epithelial hyperplasia in the female mouse small intestine. A composite uncertainty factor of 100 was used to account for intraspecies, animal-to-human, and LOAEL-to-NOAEL uncertainties. This organ/system-specific RfD (osRfD) was selected as the overall RfD. Please comment on whether the selection of the overall RfD is scientifically justified and clearly described.
    iii) EPA determined that the dataset for diffuse epithelial hyperplasia of the duodenum in female mice from (NTP, 2008) was not amenable to BMD modeling because uncertainty in estimating the BMD is too high. As a result, the LOAEL was used as the POD for toxicity value derivation of this endpoint in female mice. Female mouse hyperplasia was selected as the osRfD for gastrointestinal toxicity because females may be the more sensitive group. However, alternative approaches are presented and weighed in the toxicological review. Please comment specifically on whether the data and modeling decisions for the osRfD for gastrointestinal tract toxicity are scientifically justified and clearly described.
  b. Respiratory (noncancer outside of nasal cavity)
    i) The evidence indicates that inhalation exposure to Cr(VI) likely causes lower respiratory tract effects in humans given sufficient exposure conditions. This conclusion is primarily based on inflammatory effects indicative of lung injury in medium confidence animal studies, supported by observations of decreased lung function among chromium exposed workers in low confidence human studies and mechanistic observations that support the biological plausibility of an inflammatory tissue response following Cr(VI) exposure that is interpreted to lead to impaired function or adverse structural changes. Please comment on whether this conclusion is scientifically justified and clearly described.
    ii) A POD from Glaser et al. (1990), a 90-day inhalation bioassay in rodents, was selected to calculate an osRfC of 1 × 10^−4^ mg/m^3^ based on histopathological/cellular responses in the lung. For most endpoints that served as the basis for this osRfC, a composite uncertainty factor of 1,000 was used to account for intraspecies, animal-to-human, subchronic-to-chronic, LOAEL-to-NOAEL, and database deficiency uncertainties. Please comment on whether the selection of the selection is scientifically justified and clearly described.
  c. Respiratory (noncancer nasal cavity)
    i) As noted in Appendix A (Systematic Review Protocol), a determination that evidence demonstrates Cr(VI) causes nasal lesions in humans was adopted from the 1998 IRIS assessment. A POD from Gibb et al. (2000a) was selected to calculate an osRfC of 1 × 10^−5^ mg/m^3^ based on ulceration of the nasal septum. A composite uncertainty factor of 300 was used to account for intraspecies, subchronic-to-chronic, LOAEL-to-NOAEL, and database deficiency uncertainties. This osRfC was selected as the overall RfC. Please comment on whether the selection of the overall RfC is scientifically justified and clearly described.
  d. Hepatic
    i) The evidence indicates that Cr(VI) likely causes hepatic effects in humans given sufficient exposure conditions. This conclusion is primarily based on studies in animals that observed hepatic effects with increasing drinking water exposure levels. Increased clinical chemistry markers for liver dysfunction (ALT and AST), as well as increased chronic inflammation and fatty change were seen across animal studies. Please comment on whether this conclusion is scientifically justified and clearly described.
    - ii) A POD from NTP (2008), a 2-year drinking water bioassay in rodents, was selected to calculate an osRfD of 7 × 10^−4^ mg/kg-day based on chronic inflammation in female rats. A composite uncertainty factor of 100 was used to account for intraspecies, animal-to-human, and LOAEL-to-NOAEL uncertainties. Please comment on whether the selection is scientifically justified and clearly described.
  e. Developmental
    i) The evidence indicates that Cr(VI) likely causes developmental effects in humans given sufficient exposure conditions. This conclusion is primarily based on the observation of decreased offspring growth across most animal studies, as evidenced by decreased fetal or postnatal body weights and decreased skeletal ossification. Other outcomes in animal studies are more uncertain because they were inconsistent among high and medium confidence studies or were evaluated only in low confidence studies. Likewise, the available human data were of low confidence and difficult to interpret. Please comment on whether this conclusion is scientifically justified and clearly described.
    ii) A POD from NTP (1997), a continuous breeding study in BALBC mice, was used to derive an osRfD of 0.07 mg/kg-day based on decreased F1 offspring postnatal growth. A composite uncertainty factor of 10 was used to account for intraspecies and animal-to-human uncertainties. It should be noted that the decreased F1 offspring growth effect was observed at maternal dose of 24.4 mg/kg-day, which is a relatively high dose associated with overt toxicity in other studies. Both indirect (maternal or paternal) and direct routes of exposure to the developing organism were considered during hazard assessment. It is frequently difficult to determine whether effects on the fetus are in response to or separate from maternal toxicity in studies that report both, and so the fetal endpoints were considered in conjunction with the maternal endpoints described in the “Female reproductive effects” section. Developmental effects at doses that cause minimal maternal toxicity are still considered to represent developmental toxicity and should not be discounted as maternal toxicity (U.S. EPA, 1991). However, because this effect only occurred in high dose groups where other toxicological effects (as indicated by the lower points of departure for other toxicities) may be occurring, this osRfD was assigned low confidence. Please comment on whether the selection is scientifically justified and clearly described.
  f. Hematological
    i) Evidence suggests that Cr(VI) may cause hematological effects in humans given sufficient exposure conditions. This conclusion is based primarily on moderate animal evidence from high and medium confidence subchronic and chronic studies in rats and mice reporting consistent, dose-related, and coherent findings at 22–90 day exposures. However, the magnitude of the collective effects decreased by 12 months, with many findings returning to normal or near normal levels.
      Organ/system-specific reference doses were derived based on short-term hematological effects because factors demonstrated a credible concern for greater toxicity in a susceptible population and life stage (individuals with iron-deficient anemia, and pregnant women who are susceptible to developing iron-deficient anemia). Please comment on whether this conclusion is scientifically justified and clearly described.
    ii) A POD from NTP (2008), a 2-year drinking water bioassay in rodents, was selected to calculate an osRfD of 0.01 mg/kg-day based on decreased hemoglobin in male rats reported at 22 days. A composite uncertainty factor of 10 was used to account for intraspecies and animal-to-human uncertainties. A subchronic-to-chronic uncertainty factor was not applied because this effect was observed to ameliorate with chronic exposure. Please comment on whether the selection is scientifically justified and clearly described.
  g. Immune: Evidence suggests that Cr(VI) may modulate the immune system in humans, through both stimulatory and suppressive actions, given sufficient exposure conditions. This conclusion is primarily based on coherent evidence of effects on ex vivo WBC function across human and animal studies, antibody responses to T cell-dependent antigen measured in animals, and reduction in host resistance to bacterial infection reported in animal studies. However, confidence in the evidence was reduced because some of the studies are low confidence and reported findings often differed across studies. No reference values were derived for this system. Please comment on whether this conclusion is scientifically justified and clearly described.
  h. Male reproductive: Evidence suggests that Cr(VI) may cause male reproductive toxicity in humans given sufficient exposure conditions. This conclusion is primarily based on coherent evidence of effects across human and animal studies. Decreased testosterone and decreased sperm quantity and quality were observed in both human and animal studies; however, interpretation of this evidence was limited because most studies that observed these effects were considered low confidence and there was inconsistency with higher confidence studies. No reference values were derived for this system. Please comment on whether this conclusion is scientifically justified and clearly described.
  i. Female reproductive: Evidence is inadequate to assess whether Cr(VI) may cause female reproductive effects in humans. Although an association with female reproductive toxicity was demonstrated in a single low confidence epidemiology study and a series of low confidence animal toxicology studies, effects were not observed in medium or high confidence studies aside from a moderate decrease in maternal body weight. No reference values were derived for this system. Please comment on whether this conclusion is scientifically justified and clearly described.

### G.2.1 External Peer Reviewer Comments on Noncancer Hazard Identification and Toxicity Value Derivation (General)

The panel stated that “In general, the available information on the non-cancer effects is clearly and appropriately synthesized, including strengths and limitations to support the conclusions for each health effect presented in the draft IRIS assessment. The panel agreed that, in general, the weight of evidence decisions for hazard identification for each of the non-cancer health effects is clearly described and justified, and that health effects in susceptible subpopulations are appropriately considered. In considering the basis for the decision to use a No Observed Adverse Effect Level (NOAEL) or Lowest Observed Adverse Effect Level (LOAEL), rather than a Benchmark Dose lower bound limit (BMDL), as the point of departure (POD) for several endpoints, the panel agreed that the use of a NOAEL or LOAEL for these endpoints, in general, is appropriate and consistent with EPA Benchmark Dose (BMD) modeling guidance.” The panel provided one Tier 2 suggestion, described below.

#### G.2.1.1 Tier 1 Recommendations

The reviewers had no Tier 1 general recommendations.

#### G.2.1.2 Tier 2 Suggestions

SAB Comment: While the panel agreed with the decisions outlined in the draft IRIS assessment, the panel suggests that the EPA should mention in discussing the development of the Reference Dose (RfD, p. 4–25, Section 4.1.8) that the present value is within approximately 3-fold of the previous RfD developed in 1998.

EPA Response: This clarification has been made.

### G.2.2 External Peer Reviewer Comments on Noncancer Gastrointestinal Effects

The report states that “the panel agreed with the conclusion that oral exposure to Cr(VI) likely causes gastrointestinal (GI) tract toxicity in humans given sufficient exposure conditions. The choice of the final RfD that was based on diffuse epithelial hyperplasia in the female mouse small intestine was appropriate. Further, the panel agreed that the available data on gastrointestinal effects (noncancer) were clearly and appropriately synthesized to describe the strengths and limitations. Taken together, the weight of the available scientific information presented in the draft IRIS assessment reasonably supports the conclusion” that oral exposure to Cr(VI) likely causes GI tract toxicity.

The report also notes that “the majority of the panel agreed that the selections of the POD and composite uncertainty factor and osRfD were scientifically justified. The RfD was derived using state of practice approaches. Most of the panel agreed with EPA that the uncertainties associated with the BMD modeling (including the alternative approaches) discussed in Sections 4.1.2.2. and Appendix D.1.1.1 are too large for use of a BMDL as the POD. Most panel members also agreed with EPA that the choice of the LOAEL as the POD is appropriate and consistent with EPA BMD modeling guidance.” In addition, “the panel deemed the data and modeling decisions for the osRfD for gastrointestinal tract toxicity to be scientifically justified and clearly described.” The report did not recommend Tier 1 revisions but had several Tier 2 suggested revisions that are described below.

#### G.2.2.1 Tier 1 Recommendations

There were no Tier 1 recommendations.

#### G.2.2.2 Tier 2 Suggestions

SAB Comment: The EPA should consider for inclusion as another candidate for RfD determination using the Thompson et al., (2012; 2011) studies for BMD modeling. The EPA did not use these data (Oral RfD, GI tract pathology (see Table 4-1)) because “these studies used smaller sample sizes and shorter exposure duration” even though it was acknowledged that the range of exposures was wider in the Thompson et al., (2011; 2012) studies than in the studies used for BMD modeling. The Thompson et al. studies were commensurate with a recommended 90-day study design and, in fact, examined not only a wider range of doses, but also a greater number of doses. BMD modeling should be performed on the 90-day studies (both NTP, 2007 and the Thompson et al. data 2011, 2012) and an additional sub-chronic to chronic UF should be applied.

EPA Response: EPA now provides additional point-of-departure estimates using 90-day gastrointestinal tract data in mice from both the Thompson et al. (2011b) and NTP (2007f) studies and in rats from the Thompson et al. (2012c) study for comparison to the chronic, 2-year exposure data from the NTP (2008) study (see Tables 4-3 and 4-4). Benchmark dose modeling was only possible on male mice from NTP (2007f), and all other values required a LOAEL/NOAEL approach due to the high sudden incidence rates frequently encountered with these endpoints. Although the candidate value from the 90-day hyperplasia results in female mice from NTP (2007f) [following application of the subchronic-to-chronic uncertainty factor (UFs)] is the most consistent with the value from the 2-year NTP (2008) study, when considering additional uncertainties (i.e., subchronic data, smaller sample sizes, higher points of departure in the NTP study), the chronic 2-year RfD is still preferred.

SAB Comment: The EPA should consider performing dose-response modeling for gastrointestinal effects in the rat. While it would be helpful in characterizing the uncertainty associated with animal model selection, as a different and potentially equally relevant animal model, no GI effect PODHED comparisons are possible for the rat because none of the GI tract effects in Table 3-50 (p. 3–314) were carried forward for dose-response modeling (see Tables 4-3, 4-4, D-1, D-2, D-3).

Response: As indicated in Sections 3.2.2.2, 3.3.2.1, and Table 3-50, few effects in the rat small intestine were observed. NTP (2008) only observed histiocytic cellular infiltration, an effect of unclear biological significance, in the male and female rat small intestine at 90 days and 2 years. However, for comparative purposes, EPA has provided an analysis on the most sensitive effect, crypt cell hyperplasia, seen in the female rat small intestine in the 90-day studies by (Thompson et al., 2012c). As shown below, the lowest rat gastrointestinal candidate value would be 10× higher than the female mouse gastrointestinal RfD. Due to the sharp increase in incidence and low sample size, this endpoint was not amenable to BMD modeling, and only the NOAEL approach is presented. These results are now tabulated alongside other GI endpoints.

Table G-3 Gastrointestinal tract endpoint extrapolation for hyperplasia in the duodenum of female rats exposed for 90 days (Thompson et al., 2012c)

NOAEL mg/kg-d | Internal dose mg/kg-d | BW kg | BW^3/4^ adjust mg/kg-d | POD_HED_ mg/kg-d | Total UF | RfD
2.9 | 0.375 | 0.155 | 0.0787 | 0.270 | 30 | 0.009

SAB Comment: The EPA should consider the minimally adverse status of the noncancer GI effects in selecting the Monte Carlo Pharmacokinetic (PK) analysis percentile, as it was in the choice of a benchmark response (BMR) of 10% versus a lower value (p. 4–10, lines 7–7). To account for interindividual variability, the Human Equivalent Dose (HED) was determined by Monte Carlo analysis using the lower 1% value of 20,000 Monte Carlo PK simulations needed to achieve the internal dose POD (i.e., 0.0911 mg/kg-d in Figure D-9 on p. D-47).

EPA Response: The choice of a BMR of 10% was based on the minimally adverse status of the noncancer effects. A lower BMR and hence animal POD would have been used as a starting point for HED and RfD calculation with a more adverse endpoint (e.g., frank, or severe effects, developmental effects, fetal loss). For the Monte Carlo (MC) PBPK analysis, a choice of the 1st percentile (“lower 1% value”) from the human equivalent dose distribution (for noncancer effects) is to obtain a value that can protect the most sensitive groups in the general population based on pharmacokinetics, given the POD, independent of the adversity of the effect. So, the selection of the POD reflects adversity but then the HED calculation treats that POD as the appropriate target. (It is noted in the assessment that there may be individuals who are even more sensitive than can be estimated by modeling.) Using the 1st percentile of the MC HED distribution with a reduced intraspecies uncertainty factor of 3 for pharmacodynamics produces provisional RFDs that are about 80% higher than using the 50th percentile of the MC HED distribution, representing the HED for the average person, with the full intraspecies uncertainty factor of 10 applied. If the 5th percentile of the MC HED distribution (for the same POD) were used instead of the 1st percentile, while continuing to use UFH = 3, a further increase of less than 1.2-fold in the provisional RfD would be obtained while leaving another 4% of the population at risk of the adverse effect. As a result, EPA will continue to use the 1st percentile of the HED distribution (with a POD obtained using a 10% BMR) in this approach.

### G.2.3 External Peer Reviewer Comments on Noncancer Respiratory (Lower Respiratory Tract) Effects

The report stated that “the panel agreed that the available data on respiratory effects (noncancer outside of nasal cavity) are clearly and appropriately synthesized to describe the strengths and limitations” and “the panel agreed with the conclusion that Cr(VI) likely causes lower respiratory tract effects […] Data from human, animal toxicity and mechanistic studies all support the conclusion that Cr(VI) can cause pulmonary effects.” However, the report also states that “some members of the panel did not agree that the available data have been clearly described or appropriately synthesized. In many areas the text is too generalized, consisting merely of a reporting of the quantitative results without any interpretation relative to their magnitude or health-related significance or comprehensive analysis. All of these concerns serve to significantly diminish the quality of the draft IRIS assessment relative to effectively supporting its scientific syntheses, interpretations, and conclusions. The draft IRIS assessment could be strengthened by providing more robust and effective support of its scientific syntheses, interpretations, and conclusions.”

In addition, “the panel agreed that a major weakness of the draft IRIS assessment centers on the selection of Glaser et al., 1990 as the critical study for determining a POD. The panel noted multiple concerns related to this study and its evaluation […] EPA’s designation of this publication as a medium confidence study is unwarranted,” and went on to note multiple deficiencies with the Glaser et al. (1990) study. The panel agreed that “the EPA should clarify the inconsistencies in the presentation of some studies on human lower respiratory effects of Cr(VI),” and cited inconsistent confidence assignments for Sobaszek et al. (1998) and Huvinen et al. (2002a, 2002b), as well as conduct a more thorough analysis of altered pulmonary function in chromium workers. In addition, “the EPA should provide a more careful analysis in the bronchoalveolar lavage (BAL) response section of the draft IRIS assessment.” The report also noted that “The panel agreed that the evaluation of respiratory tract responses should be strengthened,” and pointed to “multiple instances in the text of the draft IRIS assessment where essential detail is lacking relative to particle size and characteristics.” Several Tier 1 and Tier 2 recommendations are described below.

#### G.2.3.1 Tier 1 Recommendations

SAB Comment: The EPA should reevaluate the analysis and potential use of the Glaser et al. (1990) study for POD determination […]. At the very least, the use of this study to derive a POD for pulmonary effects requires considerably more justification and qualification. If the EPA is aware of additional information on the Glaser et al., 1990 data this should be clearly stated in the IRIS assessment.

EPA Response: EPA agrees that the Glaser et al. (1990) animal study is inadequate for POD determination. EPA has removed the candidate toxicity values based on the Glaser et al. (1990) animal study, and has updated the text to indicate a strong preference for the higher quality human data for the overall RfC based on nasal effects.

SAB Comment: The EPA should directly address the issue of particle sizes in chromate aerosol exposures. Particle sizes should be explicitly stated for each study that is cited, or if the particle size is not known, this should be so stated. This applies to both experimental animal studies and to occupational epidemiological studies. That chromate aerosols are hygroscopic needs to be explicitly considered in evaluation of each study. Particle sizes should not be assumed to be similar in all occupational settings. Speculation on differing particle sizes in the workplace or general environment should be clearly indicated as such.

EPA Response: Additional information and citations regarding regional deposition of particles in the respiratory tract and particle sizes relevant to specific industries and cohorts have been added to the assessment in Section 3.1.1.2. It should be noted that particle size information is not available for the human occupational cohorts cited in the IRIS assessment; however, we have added information about observed particle sizes for the industries represented in the human studies. With regard to exposures in experimental animal studies, Section 3.1.1.2 of the assessment has been revised to clarify that the particles are hygroscopic (with cross-reference to the chemical properties table) and can change in size in the respiratory tract. Because the particle diameters used in the animal studies were small (most <0.5 μM), the particles would still be expected to deposit in the lower respiratory tract of rodents after hygroscopic growth; a citation (Asgharian, 2004) has been added to further support this. For humans, it is widely known that Cr(VI) particles generated in the chromium and steel industries, including stainless-steel welding, are inhalable and can pose a health risk.

SAB Comment: The EPA should provide a more comprehensive analysis of the animal and human response data. Health data from human and animal studies need to be more carefully described and interpreted relative to the absolute magnitude of any observed effects, the similarity/differences between animal and human responses, and the health significance of clinical observations such as labored breathing in rodents.

EPA Response: EPA has made extensive revisions to the animal and human hazard synthesis of lower respiratory tract effects. More information is provided relative to species susceptibility, endpoint interpretation, particle size and solubility, and pharmacokinetics. For human studies, where available, we have added information on authors’ interpretation of pulmonary function testing results. However, it is difficult to draw inferences regarding obstructive or restrictive patterns of deficits because the results are presented as group-level means and are not necessarily interpretable in the same way one would interpret a full profile of spirometry data at the individual level. We were also cautious in our interpretation of the outcome data because the referent population was not a match to the study population (see also detailed description in assessment text and in HAWC).

For rodent studies, the inconsistency in effects of inhaled Cr(VI) could be related to differences in study design characteristics (i.e., solubility and particle size, animal species and strain, exposure profile, and endpoint methodology). The ability to draw strong conclusions from results across studies is also limited by the small number of studies reporting each particular outcome. The lack of consistency of in vivo study designs for soluble and insoluble compounds in rodents is a major source of uncertainty.

The available human studies may have had insufficient sensitivity to detect and characterize associations between inhaled Cr(VI) and lower respiratory effects. In part this is due to lower exposure levels with passing time (e.g., due to improvements in industrial hygiene) but also differences in study design characteristics and study populations. Exposure assessment approaches varied across studies, as did ability to control for factors that could influence respiratory health outcomes (e.g., smoking, body height, or diurnal variation).

The ability to evaluate consistency between animal and human responses after inhalation exposure to Cr(VI) is complicated by the factors outlined above, and the fact that available measures of respiratory effects are different between humans (which are mostly functional responses), and rodents (which are mostly postmortem tissue analyses of sacrificed animals). In addition, rodents detoxify inhaled Cr(VI) in the respiratory tract more effectively than humans.

SAB Comment: The EPA should not exclude pulmonary function studies performed prior to 1987, since it is not scientifically justified.

EPA Response: The American Thoracic Society (ATS) guideline quality consideration for pulmonary function testing was utilized to facilitate identifying studies that were likely to be rated critically deficient in the outcome domain. However, almost all human respiratory studies published prior to ATS guidelines were not PECO-relevant for a variety of other reasons. Only one study meeting PECO criteria was found to be uninformative due to measurements predating the publication of ATS guidelines (Bovet et al., 1977), and this study also had deficiencies unrelated to ATS guidelines in the exposure and sensitivity domains that would have led to an uninformative rating. As a result, this exclusion criteria did not have an impact on the outcome of the lower respiratory tract hazard assessment.

#### G.2.3.2 Tier 2 Suggestions

SAB Comment: The EPA should modify Table 3-7 (EPA note: now Table 3-9) to include an explanation for why Cr(VI) is judged to “likely cause(s)” the effects at issue, as provided in Table 3-10 (EPA note: now Table 3-12).

EPA Response: Minor edits have been made to the existing text summarizing the rationale for the “evidence indicates” descriptor for lower respiratory toxicity in the “inferences and summary judgment” column in Table 3-9.

SAB Comment: The EPA should reconsider the database uncertainty factor (UFD) of 3. The total UF of 1,000 could perhaps be reduced to 300 following a more detailed reconsideration of the UFD value. Regardless of whether the value changes, a more detailed discussion would provide a better scientific justification of the value and this organ/system-specific Reference Concentration (osRfC).

EPA Response: EPA agrees with the SAB recommendation to reduce the database uncertainty factor for respiratory effects from 3 to 1. A large evidence base for human nasal endpoints exists, and nasal effects are believed to be the most sensitive noncancer effects of inhaled Cr(VI).

SAB Comment: The EPA should consider adding a greater level of uncertainty for this osRfC (based on Glaser et al., 1990) in Section 4.2.5 as an additional justification for selecting the osRfC based on human data from Gibb et al. (2000a) as the overall RfC.

EPA Response: EPA has removed the candidate toxicity values based on the Glaser et al. (1990) animal studies, and has updated the text to indicate strong preference for the higher-quality human data.

SAB Comment: The EPA should define vague terms used to describe Cr(VI) uptake. Throughout the text (e.g., p 3–11), there is reference to the “rapid” cellular uptake of Cr(VI) versus “slow” cellular uptake; absent is any quantitative information on the magnitude of the difference between “rapid” and “slow.”

EPA Response: A description of the timescales of fast Cr(VI) and slow Cr(III) cellular uptake, with quantified results comparing uptake in human red blood cells exposed to radiolabeled Cr(III) and Cr(VI) in vitro (Donaldson and Barreras, 1966), has been added to Section 3.1.1.1, “Extracellular reduction and absorption.”

SAB Comment: The EPA should clarify the discussion of pulmonary chromium particle deposition.

EPA Response: Additional information on regional deposition of particles in the respiratory tract is provided in Section 3.1.1.2. Study- and species-specific discussions of particle size and how this may affect deposition have been added throughout the document.

SAB Comment: The EPA should clarify the inconsistencies in the presentation of some studies on human lower respiratory effects of Cr(VI).

EPA Response: EPA has made revisions to the human hazard synthesis of lower respiratory tract effects. More information is provided relative to endpoint interpretation, particle size and solubility, and pharmacokinetics. Some human studies may have had insufficient sensitivity to appropriately characterize associations between inhaled Cr(VI) and lower respiratory effects. Interpretation of results across the human evidence base is limited by variability in exposure assessment approaches, different study populations, and lack of control for factors such as smoking, body height, or diurnal variation.

Regarding apparent inconsistency between confidence ratings, the evaluation of the exposure assessments for Sobaszek et al. (1998) and (Huvinen, 2002; Huvinen et al., 2002b) followed consistent guidelines. The Sobaszek study was considered to meet PECO criteria and was included in the evidence synthesis. Exposure to Cr(VI) was considered to be probable due to the occupational context (stainless steel welding), although the rating for the ‘Exposure’ domain is ‘deficient,’ reflecting the uncertainty regarding magnitude of exposure. In contrast, the Huvinen studies were rated ‘critically deficient’ due to lack of differentiation between exposed and referent groups – levels of both total Cr and Cr(VI) were quite low, with at least half of samples having levels below the limit of detection in most cases. This makes it difficult to differentiate levels of exposure between work sites (used to form exposure groups) and precludes the ability to discern health effects that may only occur at higher levels. This information is detailed in the study evaluations available in HAWC.

SAB Comment: The EPA should characterize the magnitude of the observed changes, specifically, whether they are considered to be mild vs. severe, etc., and whether they suggest a specific type of lung disease (e.g., obstructive, restrictive).

EPA Response: In our response to a previous comment above we described revisions that address this issue. Since that response directly addresses this comment as well, we restate it here for quick reference: For human studies, where available, we have added information on authors’ interpretation of pulmonary function testing results. However, it is difficult to draw inferences regarding obstructive or restrictive patterns of deficits because the results are presented as group-level means and are not necessarily interpretable in the same way one would interpret a full profile of spirometry data at the individual level. We were also cautious in our interpretation of the outcome data because the referent population was not a match to the study population (see also detailed description in assessment text and in HAWC.)

Regarding the Li et al. (2015b) study specifically, we agree with the SAB that the pattern of observed changes is different than might be expected, in that FVC was lower in the exposed group while the ratio of FEV1/FVC is somewhat higher. However, the absolute magnitude of the spirometry measurements is impacted by several limitations which are outlined in the assessment. As noted in Section 3.2.1.1, “Pulmonary function,” “The low percent predicted values in both the exposed and referent groups may in part reflect the high prevalence of smoking (39.56% of exposed and 28.95% of unexposed workers were current smokers), which was not accounted for in these analyses. Another possible reason for low percent predicted values across groups is that the referent group had undescribed exposure to Cr(VI) or other respiratory toxicants. Finally, it is possible that use of reference values from geographically, culturally, and ethnically different population [in this case, Japanese and European referent populations, per correspondence with study author (Jia, 2021)] could have resulted in low percent predicted values (Korotzer et al., 2000). The use of an inappropriate referent to estimate predicted pulmonary function measures may not impede comparisons of FVC and FEV1.0 between groups within the same study; however, the impact could differ for FVC compared with FEV1.0, thus there is greater uncertainty in FEV1.0/FVC results (mean [SD]: 116.18 [11.32] in exposed, 114.08 [10.79]).” Similarly, the Kuo et al. (1997) study did not account for participants’ height in computing predicted values for spirometry outcomes, complicating the interpretation of their results.

SAB Comment: The EPA should provide a more careful analysis in the bronchoalveolar lavage (BAL) response section of the draft IRIS assessment.

EPA Response: Significant revisions have been made to the sections on BAL responses. These include( 1) acknowledgement of solubility and particle size differences across studies, (2) a more streamlined discussion of effects, with a greater emphasis on whether or not the changes observed were consistent or biologically significant, and (3) expansion on possible mechanistic reasons for observed effects (or lack thereof).

SAB Comment: The EPA should correct and more carefully present the description of the macrophage accumulation data from the Glaser et al. (1990) study.

EPA Response: EPA determined that the Glaser et al. (1990) study was indeed discussing histopathological finding of peribronchial region accumulation of macrophages from the Glaser et al. (1986) study. Because Glaser et al. (1986) was rated uninformative for histopathology, and neither of the other shorter-term studies Glaser et al. (1985); Glaser et al. (1990) cite that region of the lung, this finding was removed.

SAB Comment: The EPA should clearly indicate whether the studies measured lung wet (total) weight or dry weight.

EPA Response: EPA now provides information regarding wet or dry lung weights. Most studies did not provide this information, and the lack of methodological details related to lung weight is the reason most studies were considered low confidence for this endpoint.

SAB Comment: The EPA needs to enhance the section that describes the regional particle deposition versus particle size (p. 3–39).

EPA Response: Additional information on regional deposition of particles in the respiratory tract is provided in Section 3.1.1.2. Study- and species-specific discussions of particle size data availability, and how particle size may affect deposition, have been added throughout the document.

#### G.2.3.3 Other Comments

SAB Comment (p. 13, Final SAB Report): In the Other Findings section (p. 3–33) of the draft IRIS assessment, the EPA should note as a study deficiency that none of the animal studies included examination of nasal responses. This lack of description is somewhat surprising because the effects of chromium on the nose were well known, and by the time these studies were performed, standardized approaches for examining rodent nasal responses were established.

EPA Response: As noted by the reviewer, effects of Cr(VI) on the human nasal cavity are an established effect. For this reason, EPA did not re-evaluate the qualitative evidence for an association between inhalation Cr(VI) exposure and nasal effects. This is explained in further detail in the Cr(VI) IRIS Assessment Protocol (see Appendix A). It is reasonable to assume that nasal effects would also occur in rodents (which are obligatory nose breathers), and it is possible that effects in the nasal cavity may lead to impaired breathing and other downstream impacts on the respiratory system. Because this hazard identification focuses on primary effects of Cr(VI) on the lower respiratory tract, inconsistency of reporting on nasal effects did not decrease the overall confidence of the studies or endpoints. Statements recognizing this have been added to “Other Findings” in Section 3.2.1.2. The Kim et al. (2004) study observed nasal hemorrhage in rats, and this observation was added to the section.

### G.2.4 External Peer Reviewer Comments on Noncancer Respiratory (Nasal Cavity) Effects

The panel agreed that “the selection of the overall RfC is scientifically justified, although several issues were identified that would benefit from additional analysis and discussion […] The panel believed the draft IRIS assessment should be strengthened by providing a more robust and effective description of the evidence supporting its scientific syntheses, interpretations, and conclusions. The panel agreed that the POD for nasal effects derived from Gibb et al. (2000a) should be reconsidered or at the very least more transparency is required.” The peer reviewers requested further explanation of the preference for data from certain industrial settings, stating, “A priori, one would expect there might be differences in the results from differing industries. […] If the aerosols within chromate production facilities are deemed to be more representative of environmental Cr(VI) aerosols, this should be explicitly stated.” The reviewers also requested more specificity in the described methodology, stating that “the EPA should indicate the particle sizes observed in these studies or explicitly indicate that the particle sizes are not known.” There were also questions regarding the derivation of the candidate RfC, which are responded to in more detail under Charge Question 5. The reviewers had several Tier 1 recommendations and Tier 2 suggestions, described below.

#### G.2.4.1 Tier 1 Recommendations

SAB Comment: The EPA should provide an explicit description of what is known about the exposure characteristics, including particle size, in each study followed by a detailed consideration of this fundamentally important parameter.

EPA Response: Throughout the document, information and citations regarding particle sizes relevant to specific industries and cohorts have been added to the assessment. It should be noted that particle size information is unavailable for all human occupational cohorts cited in the IRIS assessment. Information on regional deposition of particles in the respiratory tract was added to Section 3.1.1.2, and the uncertainties are discussed in Section 4.2.6.4.

SAB Comment: (Two related Tier 1 comments have been addressed here together.) The EPA should provide a more careful examination of the apparent concentration-response relationships in differing Cr(VI) occupational exposure scenarios, with more transparency relative to the selection of the critical study (Gibb et al., 2000a). The EPA should more thoroughly and transparently justify the selection of the Gibb et al. (2000a) study for POD determination.

EPA Response: Additional discussion has been added regarding acidity of chromic acid solution and its possible exacerbation of nasal effects in Section 4.2.4.1. Consideration of occupational exposure scenarios (namely, physiochemical properties of the chemicals workers were exposed to) was added to the analysis. However, EPA notes that study design differences and uncertainties make direct comparisons of quantitative results difficult across exposure scenarios. Because residential properties may be located in close proximity to chrome plating facilities, both aerosols within chromate production facilities and mists from chrome plating facilities are considered relevant to environmental exposure to Cr(VI). Neither was considered more representative of environmental exposure than the other. Though there are factors unique to each of the two industrial exposure scenarios (i.e., chrome plating plants and a chromate production plant), it is uncertain whether or in what ways these factors impact the effect of Cr(VI) exposure on the upper respiratory system. Based on notable study strengths such as the extensive exposure data and larger sample size, the dose-response data from the chromate production facility [specifically, Gibb et al. (2000a)] likely provides a better estimate of Cr(VI)-specific nasal toxicity than the two studies conducted in chrome plating facilities.

SAB Comment: The EPA should provide greater clarity in evaluating the Lindberg and Hedenstierna (1983) study regarding the LOAEL/NOAEL of specific nasal responses.

EPA Response: Significant revisions have been made to the discussions related to chromate production and chrome plating facilities in Section 4.2.4.1. The prior discussion explained that ulceration occurred in both the highest peak exposure group (20‒48 μg/m^3^) and the daily exposure group (>2‒20 μg/m^3^). The text was confusing by stating that effects occurred “only” in these groups. Effects occurred at all exposure levels, and exposure below 2 μg/m^3^ was considered the control group. Thus, there was no NOAEL.

SAB also noted in general comments that nasal atrophy was seen in the 2.5‒11 μg/m^3^ groups, and that it should be considered a toxic effect. This effect and concentration are listed in the table of dose-response data for effects in the nasal cavity of humans, and EPA considers it to be a toxic effect. The 2.5‒11 μg/m^3^ groups are specific to the peak exposures, which are not as well characterized as the longer-term data. In the synthesis, EPA chooses to emphasize data of the 8-hour time weighted average exposures (which indicate the effect above 2 μg/m^3^). This would not impact the final dose-response assessment because the chronic no-effect levels are the same as nasal ulceration.

#### G.2.4.2 Tier 2 Suggestions

SAB Comment: The EPA should consider reexamining the UFD value in more detail since other UFs are already being utilized. The EPA should also provide further discussion of the implications of PK considerations for the UFD value.

EPA Response: EPA has reduced the database uncertainty factor for nasal effects from 3 to 1 (see Section 4.2.3). EPA has made other clarifying changes to the uncertainty factors sections. These are discussed in more detail under Charge Question 5 (Uncertainty Factors).

SAB Comment: The EPA should provide a more robust justification regarding nasal septum perforation as a Cr-specific effect.

EPA Response: Additional justification has been made in Section 4.2.1.1 to indicate that these nasal effects are highly indicative of Cr(VI) inhalation exposures, particularly for the studies within the evidence base of the IRIS assessment. The nasal effects observed in workers exposed to Cr(VI) (atrophy of the nasal mucosa, ulceration of the nasal mucosa or septum, perforation of the septum, and bleeding nasal septum) are not unique to, but are highly specific to, Cr(VI) exposures, and are commonly observed in two different chromium-related occupational settings: electroplating and chromate production. The consistency across these two occupational settings provides further support that exposure to other chemicals is unlikely to be responsible, as the co-exposures in an electroplating factory are different from the co-exposures in a chromate factory. Furthermore, the development of these outcomes is considered specific to inhalation exposure to Cr(VI) due to the notably high prevalence of nasal septum perforation among workers exposed to Cr(VI), which exceeded 50% of workers in 7 chromate plants in the U.S. in the 1950s. Though other occupations exposures may contribute to nasal symptoms, there is no comparable historical prevalence among workers in industries not associated with chromium exposure. Prevalence of nasal septum perforation in the general population is only 0.5%‒3.1%, making confounding from non-industrial causes unlikely (Lanier et al., 2007; Downs and Sauder, 2023).

SAB Comment: The EPA should indicate the particle sizes observed in the cohort studies or explicitly indicate that the particle sizes are not known (p. 4–27 to 4–28).

EPA Response: Information and citations regarding particle sizes relevant to specific industries and cohorts have been added to the assessment. It should be noted that particle size information is unavailable for all human occupational cohorts cited in the IRIS assessment.

SAB Comment: The EPA should reconsider some of the UF values for noncancer respiratory nasal effects and needs to clarify the description of the UF for database uncertainty.

EPA Response: EPA has reduced the database uncertainty factor for nasal effects from 3 to 1. EPA has made other clarifying changes to the uncertainty factors sections. These are discussed in more detail under Charge Question 5 (Uncertainty Factors).

SAB Comment: The EPA should expand their discussion of particle size and deposition. The EPA should provide a better reference to support the characterization of the types of aerosols present in the workplace.

EPA Response: Information and citations regarding particle sizes relevant to specific industries and cohorts have been added to the assessment. It should be noted that particle size information is unavailable for all human occupational cohorts cited in the IRIS assessment. Information on regional deposition of particles in the respiratory tract was added to Section 3.1.1.2. Additional discussion has been added regarding acidity of chromic acid solution and its possible exacerbation of nasal effects.

### G.2.5 External Peer Reviewer Comments on Noncancer Hepatic Effects

The panel agreed that “Cr(VI) clearly causes liver toxicity, given the elevation of liver enzymes seen following exposure and dose/response in liver toxicity in animal studies.” The panel agreed that “these conclusions are scientifically justified and require only a few minor corrections for clarity.” Several Tier 1 and Tier 2 recommendations are described below.

#### G.2.5.1 Tier 1 Recommendations

SAB Comment: The utility of the ALT data to POD derivation is questionable and EPA should consider excluding them from the dose-response analyses.

EPA Response: ALT is a well-established serum biomarker, with ALT increases exceeding twofold being an indicator of concern for hepatic injury (Sawicka and Długosz, 2017; EMEA, 2010; Boone et al., 2005). Despite stated difficulties related to dose-response modeling (e.g., steep dose-response relationship, and higher effects at short-term vs. chronic exposures), EPA maintains that the ALT increases observed in animal bioassays were indicators of concern for hepatic injury, and that some datasets were suitable for the dose-response assessment. While a candidate value was derived for increased ALT, along with several histological effects, it was not ultimately selected as the osRfD for hepatotoxicity (see Section 4.1.3.2).

SAB Comment: Although reasons for the difference in responses with route of exposure are addressed elsewhere, a brief summary and reference to where in the draft IRIS assessment this issue is discussed should be provided in the body of the document. For example, in discussing the clinical chemistry results in animals (p. 3–172, lines 14–20), it was noted that “significant increases in serum markers of liver damage were reported in several high and medium confidence oral exposure studies.” However, the draft IRIS assessment then notes that “No effects on serum markers of liver damage were reported following inhalation exposures.”

EPA Response: Information regarding the first-pass effect following oral exposure has been added to the “Clinical chemistry” subsection in Section 3.2.4.2, with reference to pharmacokinetic sections. It is explained that the liver may be affected more severely by Cr(VI) exposure via the oral route as compared with the inhalation route.

#### G.2.5.2 Tier 2 Suggestions

SAB Comment: The EPA should provide more details and explanation for conclusions about the categorization of animal studies. The subsection on animal study evidence lists 18 studies whose results are categorized as high confidence, medium confidence, low confidence, or uninformative, based on the parameter being determined. A couple of the conclusions regarding liver histopathology and inflammation are presented with a fair bit of uncertainty and in a manner that contribute to a lack of confidence in the conclusion.

EPA Response: Detailed information on study evaluation conclusions for the available animal studies for Cr(VI) liver effects can be found in the interactive version of the overall confidence classification summary table (see Table 3-25) in HAWC. Regarding the conclusions on liver histopathology in animal models, revisions were made in Section 3.2.4.4. to clarify conclusions and uncertainties regarding the animal hepatic histopathology and inflammation findings, especially regarding apparent species and sex differences (discussed in more detail below).

SAB Comment: The EPA should provide additional discussion about the validity of the conclusion about female rodents being more sensitive than male rodents. On p. 3–169, lines 11–13: The draft IRIS assessment states: “In general, female rodents appear to be more sensitive to Cr(VI) induced histological changes (e.g., hepatic inflammation and fatty changes; NTP (2008)). However, few studies are available in the database that evaluated both males and females…”

EPA Response: Text has been revised to emphasize that the observed female sensitivity was only observed in the one study that examined this endpoint in both sexes. There are major exposure variables that differ between studies in the evidence base (e.g., exposure length, dietary vs. drinking water exposure, lifestage). Few studies consistently exposed both species, and both sexes, using the same exposure protocols. As a result, there is uncertainty as to whether rats are more susceptible than mice, or if females are more susceptible than males, to these particular Cr(VI)-induced hepatic effects. A statement to this effect was added to the final integration of evidence section (see Section 3.2.4.4).

SAB Comment: The EPA should provide additional discussion about the absence of increases in chronic inflammation and histiocytic infiltration in male mice. The draft IRIS assessment states (p. 3–169, lines 20–23): “For mice, which generally appeared to be less sensitive than rats to hepatic effects with Cr(VI) exposure, statistically significant increases in chronic inflammation and histiocytic infiltration were seen in female, but not male mice (NTP, 2008).”

EPA Response: We have removed the statement indicating that mice were “generally less sensitive than rats” in addition to statements that females were “generally” less sensitive than males, since these observations pertain to only the limited scope of studies that examined both males and females, and/or both rats and mice. There are major exposure variables that differ between studies (e.g., exposure length, dietary vs. drinking water exposure, lifestage). Few studies consistently exposed both species, and both sexes, using the same exposure protocols. As a result, there is uncertainty as to whether rats are more susceptible than mice, or if females are more susceptible than males, to these particular Cr(VI)-induced hepatic effects. A statement to this effect was added to the final integration of evidence section (see Section 3.2.4.4).

### G.2.6 External Peer Reviewer Comments on Noncancer Developmental Effects

The panel agreed that “the overall conclusion on the developmental effects from Cr(VI) exposure is scientifically justified and clearly described. […] It is likely that Cr(VI) causes developmental toxicity based on decreased offspring growth across most animal studies, decreased fetal and body weights and decreased skeletal ossification.” In addition, “the selection of organ-specific RfD (osRfD) for development toxicity (0.07 mg/kg-d) is scientifically justified and clearly described.” The panel noted that “while the body of evidence of the developmental effects of Cr(VI) comes mainly from animal studies, the number of human studies is probably larger than the ones summarized” in the assessment, and that “human data were of low confidence and difficult to interpret.” The panel recommended additional studies to include as Tier 3 future considerations, with the rationale that “incorporating newer human studies may add clarity to the findings related to birth weight and preterm birth in humans,” but acknowledging that “inconsistency may still persist given the discrepancies between these study findings.” The reviewers had no Tier 1 recommendations, but several Tier 2 suggestions and Tier 3 considerations are described below.

#### G.2.6.1 Tier 1 Recommendations

The reviewers had no Tier 1 recommendations.

#### G.2.6.2 Tier 2 Suggestions

SAB Comment: The EPA should reevaluate the “low confidence” designation for the Hjollund et al. (2005, 2000, 1995) and JP et al. (1992) studies.

EPA Response: These studies were all rated as “deficient” for the exposure domain, consistent with the systematic review protocol (see Appendix A, Section 6.2.1). See HAWC (https://hawc.epa.gov/summary/visual/assessment/499/heatmap-crvi-developmental-epidemiology-studies/) for full study evaluation details.

SAB Comment: In this section, the EPA should explain in more detail why these studies (Xia et al., 2016; Quansah and Jaakkola, 2009; Ren et al., 2003; Chen et al., 1997) were found to be uninformative, as was done in other parts of the draft IRIS assessment for epidemiological studies and especially animal studies.

EPA Response: Additional, but minimal, details have been added to the summary of study evaluation findings for the human evidence of developmental effects (see Section 3.2.9.1). Note that, because the full evaluations are available in HAWC (link (https://hawc.epa.gov/summary/visual/assessment/499/heatmap-crvi-developmental-epidemiology-studies/)), only concise descriptions of uninformative studies are added to the toxicological review.

SAB Comment: The EPA should better explain and justify the inclusion of two studies (p. 3–284, Remy et al., 2017; Eizaguirre-García et al., 2000) using geographically-based measures of exposure.

EPA Response: Ecologic studies can provide valuable information on unique exposure scenarios. While there is potential for ecologic fallacy in these studies, they are not automatically excluded.

SAB Comment: The EPA should interpret the epidemiological evidence as unsupportive of an association with developmental outcomes due to significant study limitations and inconsistent findings, rather than calling the evidence “slight” and “uncertain.”

EPA Response: Additional detail has been added to the evidence integration text to provide clarity on the interpretation of epidemiological findings, which, although considered to be slight due to a lack of consistency across the human studies that reduces certainty in an association, does include observations of a large effect size of a sensitive outcome (spontaneous abortions) in a study with an expected bias toward the null (Hjollund et al., 2000).

SAB Comment: The EPA should more carefully interpret data on fetal and postnatal growth (see Section 3.2.9) due to discrepancies between results of various studies. The conclusion about the effect of chromium on developmental outcomes based on these specific responses may need to be revised.

EPA Response: In Section 3.2.9.2, EPA now includes possible rationales for different outcomes between the broader database that reported effects on F1 growth and the three studies that reported no effect on F1 growth. The inconsistencies may be due to different dose levels and profiles, as well as differences in endpoint sensitivity due to timing of data collection, increasing certainty in the judgment that the animal evidence is moderate for developmental effects.

#### G.2.6.3 Tier 3 Considerations

SAB Comment: The low confidence animal studies should be more thoroughly scrutinized to understand the difference in the observed effects between them and the two high and one medium confidence animal studies that had differing conclusions regarding pre- and post-implantation loss.

EPA Response: Study evaluations provide multiple potential explanations for the discrepancy in findings between low and medium or high confidence studies. The main issues with the low confidence developmental animal studies, which can be found in full in the HAWC database (link (https://hawc.epa.gov/summary/visual/assessment/499/Heatmap-developmental-animal/)), were using very high dose levels, scientific integrity, missing information on chemical source or purity, and data presentation. As discussed in the evidence synthesis in Section 3.2.9.2, "The studies by Arshad et al. (2017) and Samuel et al. (2012) presented results in terms of the number of individual fetuses affected without indication of means or variance across litters, so there is greater uncertainty in the results of these studies."

SAB Comment: The EPA should incorporate the following newer human studies in this assessment. Doing so may add clarity to the birth weight and preterm birth findings in humans. Yet, inconsistency may still persist given the discrepancy in these study findings.

EPA Response: EPA is providing a table outlining PECO screening for each of the studies in Table G-4 below. Each of the studies uses an exposure measure of total chromium, and thus would be ‘deficient’ or lower (i.e., ‘critically deficient’) for the exposure measurement domain and unlikely to have a substantial impact on the assessment conclusions. Further, results are inconsistent across the studies.

Table G-4 Overview of recent human developmental studies identified by the Science Advisory Board

Reference | Notes
Galarneau et al. (2022) | Study meets PECO but uses an exposure measure of total chromium (based on welding hours with urine validation). Some inverse associations with fetal weight observed, but inconsistent across outcome measurement timing.
Dou et al. (2022) | Study meets PECO but uses an exposure measure of total chromium (urine). A positive but not statistically significant association with fetal loss (OR 1.22), no association with gestational age at birth or birth weight.
Howe et al. (2022) | Study meets PECO but uses an exposure measure of total chromium (urine). No association with birth weight.
Comess et al. (2021) | Study meets PECO but uses an exposure measure of total chromium (moss). Positive but not statistically significant association with very preterm but not all preterm births, no association with small for gestational age.
Huang et al. (2020) | Study meets PECO but uses an exposure measure of total chromium (blood). Inverse association with anogenital distance.
Kim et al. (2020) | Study meets PECO but uses an exposure measure of total chromium (maternal blood). Positive but not statistically significant association with small for gestational age in one of the two study sites.
Freire et al. (2019) | Study meets PECO but uses an exposure measure of total chromium (placental tissue). No association with birth size or preterm birth.

### G.2.7 External Peer Reviewer Comments on Noncancer Hematologic Effects

The panel agreed that “with sufficient exposure conditions, Cr(VI) causes hematological toxicity, which was enhanced with iron-deficient anemia and during pregnancy. This conclusion was appropriate.” In addition, “the panel considered an osRfD of 0.01 mg/kg calculated based on a 22-day male rat study and the use of an uncertainty factor of 10 [is] appropriate.” The reviewers had no additional comments.

#### G.2.7.1 Tier 1 Recommendations

The reviewers had no Tier 1 recommendations.

#### G.2.7.2 Tier 2 Suggestions

The reviewers had no Tier 2 suggestions.

### G.2.8 External Peer Reviewer Comments on Noncancer Immune Effects

The report states that “the panel agreed that both animal and human studies indicate that Cr(VI) has suppressing effects on the immune system. However, some of the studies available in the literature are “low confidence” with findings that show differing effects depending on the study. The panel agreed that the conclusions are sufficient and justified based on the available studies.” No additional comments were included.

#### G.2.8.1 Tier 1 Recommendations

The reviewers had no Tier 1 recommendations.

#### G.2.8.2 Tier 2 Suggestions

The reviewers had no Tier 2 suggestions.

### G.2.9 External Peer Reviewer Comments on Noncancer Male Reproductive Effects

The panel agreed that “in general, the available data on male reproductive effects are clearly and appropriately synthesized to describe the strengths and limitations.” The panel agreed that “the human evidence for male reproductive effects is slight, as is the laboratory animal evidence.” The report states that “the draft IRIS assessment (see Section 3.2.7) also contains information relevant to and supporting the weight-of-evidence for male reproductive effects. Taken together, the weight of the available scientific information presented reasonably supports that with sufficiently high exposure over a sufficiently long duration (i.e., “given sufficient exposure conditions” as stated in Table 3-42), Cr(VI) exposure may cause male reproductive toxicity in the general human population, including potentially susceptible subpopulations.” The reviewers had no Tier 1 recommendations; one Tier 2 suggestion is presented below.

#### G.2.9.1 Tier 1 Recommendations

Reviewers had no Tier 1 recommendations.

#### G.2.9.2 Tier 2 Suggestions

SAB Comment: EPA needs to clarify how they developed the suggestive conclusion given sufficient exposure, because EPA also says the “evidence of an association between Cr(VI) exposure and male reproductive effects in humans is slight.” Similarly, that evidence was slight in animal studies and mechanistic studies. While the review panel agrees that the evidence is suggestive, the addition of the statement “may cause male reproductive toxicity in humans given sufficient exposure conditions” in humans can be confusing because it implies causality. “May potentially” is a better way to phrase this statement. This comment pertains to other places in the Review using the same terminology.

EPA Response: The IRIS Handbook describes the “suggestive” evidence integration judgment as: “The currently available evidence suggests that [chemical] [underlined: might] [emphasis added] cause [health effect] in humans (U.S. EPA, 2022b). This conclusion is based on studies of [humans or animals] that assessed [exposure or dose] levels of [range of concentrations or specific cutoff level concentration],” with might generally referring to something less likely to occur than may. Note that this narrative also does not include mention of “sufficient exposure conditions,” given that toxicity values are typically not derived for hazards with this descriptor (although exceptions are made, such as hematologic effects in the Cr(VI) assessment due to the potential susceptibility of pregnant women). EPA has corrected the descriptor narratives for male reproductive, immune, and hematologic effects.

### G.2.10 External Peer Reviewer Comments on Noncancer Female Reproductive Effects

The report states that” the panel agreed with EPA’s conclusion that the evidence is inadequate to assess whether Cr(VI) may cause female reproductive effects in humans. The available data on female reproductive effects are clearly and appropriately synthesized to describe the strengths and limitations. […] The bases for this weight-of-evidence decision are clearly described in the text.” There were no Tier 1 or Tier 2 comments.

#### G.2.10.1 Tier 1 Recommendations

The reviewers had no Tier 1 recommendations.

#### G.2.10.2 Tier 2 Suggestions

The reviewers had no Tier 2 suggestions.

### G.2.11 Public Comments on Noncancer Hazard Identification and Toxicity Value Derivation

Several comments were received that disagreed with EPA’s interpretation of histopathological data of the gastrointestinal tract of rodents for the syntheses of noncancer and cancer GI tract health effects and cancer MOA. These comments are relevant to both Charge Questions 3 and 6 but have been summarized with the public comments on Charge Question 6, cancer hazard identification and toxicity value derivation, in Section G.5.2.

Public Comment: One commenter stated that EPA’s selection of studies for dose-response analysis and derivation of candidate RfDs is clear and well-justified, but that insufficient justification was provided for selection of GI tract effects rather than liver effects for the overall RfD.

EPA Response: In consideration of the minimal severity of the chronic inflammation observed in female rats in the two year bioassay [characterized by NTP 2008 as a “chronic inflammatory process of minimal severity” and “consistent with changes that are considered to be background or spontaneous lesions commonly observed in aged rats” (NTP, 2008)], the histological lesion of diffuse epithelia hyperplasia in the GI of female mice was preferred as the basis of the overall RfD. SAB was asked in Charge question 3aii about the selection of the overall RfD based on GI effects. They included in their response to Charge question 3ai: “The choice of the final RfD that was based on diffuse epithelial hyperplasia in the female mouse small intestine was appropriate.” The panel also states under charge question 4 on benchmark dose modeling: “The panel…agreed that selection of the POD for this effect [diffuse epithelial hyperplasia] in females was the correct basis for derivation of the final RfD.” Section 4.1.4 has been revised to provide additional clarity on the selection of GI lesions as the basis of the overall RfD over the liver lesions.

Public Comment: One commenter stated that EPA discussion regarding effects on the immune system is seriously flawed because it relied predominantly on in vitro and animal studies. Commenter stated the immune system in rodents is considerably different from that in humans, and effects in rodents are not predictive of effects in humans.

EPA Response: The field of toxicology has historically relied upon experimental studies in nonhuman species, in part because it would be unethical to test human subjects [for a more extensive explanation, please see Klaassen (2019)]. As noted by EPA guidance, without evidence to the contrary, responses in animals are presumed relevant to humans (U.S. EPA, 2005a). This position is shared by the World Health Organization’s Guidance for Immunotoxicity Risk Assessment for Chemicals (Ipcs, 2012), which states, “positive results demonstrating that a test article causes immunotoxicity in laboratory animals under the conditions of the study are assumed to be relevant to humans, unless data are available that demonstrate otherwise.” In addition, as is detailed in the WHO Guidance, reliance on animal exposure-effects studies is standard practice for the detection and characterization of immunotoxicity, and notes that for reaching conclusions of sufficient evidence for immunotoxicity, the evidence may include studies in humans, “…or in one or more laboratory animal species that indicate a dose- and treatment-related effect on disease resistance assays and/or other parameters predictive for immunotoxicity (e.g., a local lymph node assay [LLNA] result indicating a contact sensitizer or a decrease in a functional measure of immunity, such as antigen-specific antibody production) that is not secondary to overt systemic toxicity.”

In the case of immune effects of Cr(VI), the overall judgment of suggestive evidence was based on a similar weight of evidence from both human and animal studies; as noted in the SAB Charge Question 3g, “confidence in the evidence was reduced because some of the studies are low confidence and reported findings often differed across studies.” The evidence was supported by in vitro findings, but the overall conclusion did not rely primarily or even significantly on in vitro data (see Section 3.2.6). Effects on the immune system were organized such that the lines of evidence were organized into two categories (i.e., informative and supporting) that were derived entirely from in vivo animal studies and ex vivo assessments of exposed animals. In this evidence integration, in vitro evidence was used to provide mechanistic support for evidence derived from PECO-relevant animal studies. The SAB was asked in Charge Question 3g about the judgment that the evidence suggests that Cr(VI) might cause immune effects; they stated that “the panel agreed that both animal and human studies indicate that Cr(VI) has suppressing effects on the immune system. […] The panel agreed that the conclusions are sufficient and justified based on the available studies.”

## G.3 CHARGE QUESTION 4 - BENCHMARK DOSE MODELING

EPA used benchmark dose (BMD) modeling to identify points-of-departure (PODs) for the following Cr(VI)-induced health effects observed in rodents: respiratory, gastrointestinal (cancer and noncancer), and hepatic. Are the modeling approaches used, selection and justification of benchmark response levels, and the selected models used to identify each POD for toxicity value derivation scientifically justified and clearly described?

### G.3.1 External Peer Reviewer Comments on Benchmark Dose Modeling

The peer review report states “the panel agreed that, in general, the modeling approaches, model selection process, and benchmark response (BMR) levels used to identify PODs for toxicity value derivation for both non-cancer and cancer effects follow EPA guidance and are scientifically justified. They also agreed with EPA’s rationale for concluding that a NOAEL or LOAEL should be used as the POD because BMD modeling is not supportable for some endpoints.” However, the report also notes that “the rather complex approach for determining the HED was developed specifically for oral exposure to Cr(VI), and it was not necessarily intuitive as to why both the PK model and the BW^3/4^ adjustments were made.” Two Tier 1 comments are discussed below.

#### G.3.1.1 Tier 1 Recommendations

SAB Comment: The explanation for the approach in Section 4.2.1.1 PBPK Modeling and Animal-to-Human Extrapolation [EPA note: the correct section is 4.1.2.1] in the draft IRIS assessment should be expanded so that the rationale for using both adjustments to determine the internal human dose is more evident. A clear explanation was provided on p. C-17 in Section C.1.5.1 of Appendix C in the Supplementary Information, and this explanation could be used as the starting point for revision of the main draft IRIS assessment.

EPA Response: Additional clarifications regarding the need and justification for BW^3/4^ scaling have been provided throughout the document in both cancer and noncancer sections. BW^3/4^ scaling was applied to account for size or surface area differences between test animals and humans. Text indicating that metabolic clearance was also a rationale has been removed.

SAB Comment: Although Charge Question 6 addresses only cancer effects, the panel agreed that the recommendation for the EPA to further consider using toxicokinetic principles (specifically, dose-dependency in the fraction of chromium dose accumulated) also applies to the dose-response modeling for non-cancer effects that is considered here in Charge Question 4.

EPA Response: EPA has developed new subsections (see Section 3.1.2.2, discussing possible pharmacokinetic mechanisms; Section 4.1.5.7, describing the impact of nonlinearity from an alternate approach for the RfD; and Section 4.3.5.1, describing an alternate analysis of intestinal tumors using tissue doses) assessing potential low-dose nonlinearities in the GI tract. EPA’s gastric PBPK model is now shown to adequately describe the nonlinearity in intestinal tissue dose (see Figures 3-12 to 3-14, Section 3.1.2.2) and EPA has adjusted its analysis of small intestine tumors to more fully account for nonlinearity in the intestinal dose by using that internal dose when conducting BMD modeling for the mouse intestinal tumors and obtaining an (internal dose) POD using a 1% BMR before calculating the HED. (The candidate OSF for this endpoint is then calculated as 0.01/HED(1% BMR), Section 4.3.3.) This change in approach resulted in a reduction in the candidate OSFs of about 3-fold.

Because humans reduce Cr(VI) more effectively at low doses, this revised analysis of small-intestine tumor data shifted the animal-to-human extrapolation to a lower dose range, resulting in a significant increase in the human equivalent dose and decrease in the resulting slope factors. Subsequent to this change, the most sensitive cancer endpoint is identified as the oral tumor response in female rats, for which the ingested dose is selected as the dose-metric, since there is no opportunity for gastric reduction prior to contact with the oral cavity, with animal-human extrapolation via BW^3/4^ scaling to account for the likelihood of slower clearance in the oral epithelium. For the oral tumors endpoint extrapolated from female rats, the OSF is 0.16 (mg/kg-day)^-1^, which is slightly lower than the estimate based on mouse small-intestine tumors presented in the draft assessment (i.e., 0.3 (mg/kg-day)^-1^). However, the OSF estimated from oral tumors in female rats is then approximately 60% higher than the revised OSF for intestinal tumors, and no nonlinearity in tissue dose is expected for the portal-of-entry effect. (Note that the HEDs and slope factors discussed here are for human adults. Age-dependent adjustment factors for additional risk from childhood exposure are applied in the assessment resulting in higher estimated risks when childhood exposure is included.)

For key noncancer GI and liver effects (which were not amenable to BMD modeling), an alternate approach was evaluated in which two of the uncertainty factors were applied to the PBPK-estimated internal doses before HED calculation, rather than after HED calculation (see Section 4.1.5.7). This alternate approach reduced the internal dose used for HED calculation by 3-or 30-fold while keeping the same composite UF. However, the resulting candidate RfD, based on intestinal hyperplasia in the mouse, only increased 11% (i.e., from 9 × 10^−4^ to 1 × 10^−3^ mg/kg-day) using this alternate approach. The relatively minor difference is attributed to the current analysis already being in the range of linear internal dosimetry. Since this alternate approach is otherwise inconsistent with EPA’s standard practice of applying all noncancer uncertainty factors after HED determination, and only had a minor impact, the RfD presented in the draft assessment was not revised. EPA notes that the RfD does use the gastric PBPK model for animal-human extrapolation, and so accounts for animal-human differences in gastric reduction at the POD.

In addition, EPA concludes that other suggested mechanisms of PK nonlinearity are not scientifically consistent with the molecular kinetics of diffusion and transporter-mediated uptake. Specifically, EPA illustrates that (1) mucus would not be a barrier for uptake of water-soluble elements into the GI tract, (2) Cr(VI) compounds are rapidly absorbed into cells and tissues regardless of Cr(VI) concentration, (3) the gastric PBPK model appropriately accounts for gastric reduction, the sole contributor to low-dose nonlinearity in rodents, (4) very low oral doses of Cr(VI) (i.e., below the minimum reporting level) can be absorbed by the small intestine in humans, and (5) a greater Cr(VI) dose is expected to escape stomach reduction as the oral dose increases, not decreases (see Section 3.1.2.2).

#### G.3.1.2 Tier 2 Suggestions

Reviewers had no Tier 2 suggestions.

#### G.3.1.3 Other Comments

SAB Comment: Regarding Charge Question 4, the panel also recommended that the EPA consider models that are sublinear over the lower part of the dose-response, as well as the multistage degree 1 model selected by EPA for dose-response modeling of the mouse small intestinal tumor data if/when oral dose is the dose metric. The panel agreed that PODs (male -BMDL; female – LOAEL) for diffuse epithelial hyperplasia in the mouse small intestine were developed using appropriate approaches. The panel noted that these PODs are already presented in the draft IRIS assessment and agreed that selection of the POD for this effect in females was the correct basis for derivation of the final RfD. Furthermore, it was noted that the draft IRIS assessment already includes an evaluation of an alternate threshold MOA based on this RfD (see Section D.3.3 in the draft IRIS Supplemental Information document).

EPA Response: For tumors of the small intestine in mice, there was a negligible difference between the multistage models. For male mice with a 1% BMR using internal dose (dose escaping reduction in the stomach), all higher-degree BMDLs were 0.0214 mg/kg-day, compared with 1 degree multistage, which was 0.0208 mg/kg-day. For female mice, all multistage models were identical to 3 significant figures (BMDL of 0.0232 mg/kg-day with a 1% BMR using internal doses). As illustrated in Appendix D.8.5, the male mouse intestinal tumors response is essentially linear with internal dose over the entire dose-response range. For female mice (see Appendix D.8.6), the data suggest a saturation of effect between the two highest doses and a slight super-linearity among the four lower doses, but the fit of the 1st degree multistage model is quite consistent with the responses in the controls and lowest two doses. Having converted to use of internal doses in the dose-response analysis, the EPA does not find sufficient evidence in the intestinal tumor response data to support additional degrees of freedom in the statistical dose-response modeling.

### G.3.2 Public Comments on Benchmark Dose Modeling

Public Comment: One commenter objected to the use of a LOAEL in the derivation of the RfD for diffuse epithelial hyperplasia in female mice, stating that the BMD modeling provided acceptable POD options (see also public comment under Charge Question 5 in Section G.4.2).

EPA Response: Due to the uncertainties, EPA declines to use BMD results for female mouse hyperplasia from NTP (2008); see Section 4.1.5.6 (“Uncertainty in Dose-response Modeling”) for details. EPA’s LOAEL-to-NOAEL approach for diffuse epithelial hyperplasia of the female mouse duodenum was supported by a majority of the external peer review committee. The final SAB report can be found here (https://sab.epa.gov/ords/sab/f?p=100:0:9977951253767:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1121). Please also see the responses to the external peer reviewer comments above.

## G.4 CHARGE QUESTION 5 - UNCERTAINTY FACTORS

EPA applied a series of five UFs to the POD developed for each noncancer related endpoint/study, specifically addressing the following areas of uncertainty: intraspecies uncertainty (UF_H_) to account for variation in susceptibility across the human population, and the possibility that the available data may not be representative of individuals who are most susceptible to the effect; interspecies uncertainty (UF_A_) to account for animal-to-human extrapolation, and consisting of equal parts representing pharmacokinetic and pharmacodynamic differences; subchronic-to-chronic uncertainty (UF_S_) to account for the uncertainty in using subchronic studies to make inferences about lifetime exposure, and to consider whether lifetime exposure would have effects at lower levels (e.g., for studies other than subchronic studies); LOAEL-to-NOAEL uncertainty (UF_L_) to infer an exposure level where effects are not expected when a POD is based on a lowest-observed-adverse-effect level (LOAEL); and database uncertainty (UF_D_) to account for database deficiencies if an incomplete database raises concern that further studies might identify a more sensitive effect, organ system, or life stage.

a. Has uncertainty been adequately accounted for in the derivation of the reference values? Please describe and provide recommendations, if needed.
b. To inform uncertainty in intraspecies variability, UF_H_, the assessment evaluates and considers the available evidence on potential susceptibility to Cr(VI) within different populations or lifestages, including any potential human health impacts from early life exposure. Monte-Carlo analysis using pharmacokinetic modeling was applied to account for pharmacokinetic variability in the average/general adult population following oral exposure. As a result, for effects via the oral route, the UF_H_ was lowered from 10, and 3 was retained for pharmacodynamic variability. However, there may be residual pharmacokinetic variabilities for susceptible populations outside the capabilities of the standard adult-based model. These cannot be quantified and are discussed qualitatively in the assessment. Is the rationale for a UF_H_ of 3 scientifically justified and clearly described?
c. A database uncertainty factor, UF_D_, of 3 was applied to inhalation respiratory effects (both human nasal and animal lower respiratory). A value of less than 10 was applied because respiratory tract effects of inhaled Cr(VI) are considered portal-of-entry effects, and are therefore likely to be amongst the most sensitive based on current understanding of pharmacokinetics and mechanisms following inhalation. A value of UF_D_ = 3 (as opposed to UF_D_ = 1) was applied because many of the inhalation studies were low-confidence (particularly for noncancer effects outside the portals of entry) and limited in scope (working-age and mostly male humans, and only male rodents). Due to pharmacokinetic differences from oral exposure (Cr(VI) is detoxified in the gut and liver on first-pass), the stronger oral database (UF_D_ = 1 for all effects following oral exposures) could not be used to inform the UF_D_ for inhalation effects. Is the rationale scientifically justified and clearly described?
d. A subchronic to chronic uncertainty factor, UF_S_, of 3 was applied to human nasal effects. While data were not from chronic lifetime exposures, the nasal effects were observed to have a short onset time. This may indicate that nasal effects occur following short-term occupational exposures to high concentrations of Cr(VI), when significant impaction of large particulates or mists containing Cr(VI) occurs along the nasal passages. Givin the available evidence, it is considered less likely that exposure to Cr(VI) outside of occupational settings (where particulates are larger) would induce nasal perforations/ulcerations at much lower concentrations and smaller particle sizes. As a result, a factor of UF_S_ < 10 was applied. Because it is possible that prolonged exposures to high concentrations may increase the severity of existing nasal lesions after they occur, a value of UF_S_ = 3 (as opposed to UF_S_ = 1) was applied. Is the rationale scientifically justified and clearly described?

### G.4.1 External Peer Reviewer Comments on Uncertainty Factors

The panel “agreed that the draft IRIS assessment generally provides an adequate description of the choices made and the UF types,” while providing a number of Tier-2 suggestions. The panel “concluded that the [inhalation] UF_D_ value of 3 should be reevaluated more comprehensively in the context of the other UF_s_ already being used, as well as the implications of mechanistic evidence … and other relevant PK evidence with regard to the potential for more sensitive remote effects,” adding that “relevant PK factors include (but are not limited to) considerations such as, while inhaled Cr(VI) is primarily distributed to the respiratory tract and can escape extracellular reduction to enter systemic circulation (Section 3.1.1), there is rapid uptake by red blood cells (RBCs) and reduction of Cr(VI) to trap Cr(III) within RBCs (Figure 3-1, p. 3–2). The ability of PBPK modeling to estimate the approximate inhalation exposures required to achieve the same order of systemic distribution as systemic effects resulting from oral exposure (e.g., hematological, hepatic; Table 4-3) should also be compared with the inhalation LOAELs/BMDs available. A discussion of the implications of these types of considerations for the UF_D_ value would serve to increase the scientific justification of the UF_D_ value and the overall RfC value.” The panel also noted that “even though there is potentially residual pharmacokinetic variability not accounted for by the PBPK model, the panel agreed that a UF_H_ of 3 to account for pharmacodynamic variability in development of the RfD is appropriate and sufficiently protective. This relationship is particularly true because the POD is based on the lower 1% value from the Monte Carlo simulations. This selection is a conservative choice for this admittedly minimally adverse effect (see Section 4.1.2.2, p. 4–10).” In addition, “EPA has provided a rationale for the [subchronic to chronic] UF (UF_S_) of 3, although the justification could perhaps be better clarified and/or strengthened,” but that “the intent of using a value of 3 seems to be to reduce the severity of nasal lesions induced by Cr(VI) rather than protecting against them in the first place.”

#### G.4.1.1 Tier 1 Recommendations

There were no Tier 1 recommendations.

#### G.4.1.2 Tier 2 Suggestions

SAB Comment: The panel recommended that the IRIS assessment should mention on p. 4–14, lines 22–30 that the EPA (2011) guidance document, Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose, states that an interspecies UF of 3 instead of the default UF_A_ of 10 should be applied when body weight^3/4^ scaling is used.

EPA Response: This clarification has been made.

SAB Comment: If the overall intraspecies variability, including the more susceptible populations, is still accounted for by a UF_H_ of 3, this needs to be more clearly explained in the text.

EPA Response: Clarifications have been made regarding the intraspecies uncertainty factor (UF_H_). There are some variabilities and susceptible populations where uncertainty cannot be quantified.

SAB Comment: The panel suggests that in light of the considerations highlighted in the report, a UF_D_ value of 1 is more appropriate for human inhalation PODs.

EPA Response: EPA has reduced the database uncertainty factor (UF_D_) for nasal effects from 3 to 1.

In response to the general UF_D_ comment suggesting EPA use PBPK modeling to approximate inhalation exposures required to achieve the same order of systemic distribution as systemic effects resulting from oral exposure (see general SAB comments above), EPA determined that PBPK models were insufficient for route-to-route extrapolation approaches, and that quantitative route-to-route extrapolations would not be performed in the assessment. This is now stated in Sections 3.3.2, 4.1.1, and 4.3.1.

SAB Comment: The EPA should consider adding further justification for not using a value of UF_S_ = 1 for human nasal effects.

EPA Response: Text in Section 4.2.3 related to the UF_S_ for human nasal effects was revised. Rationale is now focused on the fact that a 10× higher incidence is not possible with prolonged exposures because incidence is already high (thus, UF_S_ < 10), but that prolonged environmental exposure may either induce or exacerbate nasal effects (thus, UF_S_ > 1).

### G.4.2 Public Comments on Uncertainty Factors

Public Comment: One public commenter states that EPA inappropriately inflated the composite uncertainty for diffuse epithelial hyperplasia. The commenter claims that the BMD modeling software provided acceptable POD options, and that EPA should use the BMD model results (thereby obviating the need to apply a 10-fold LOAEL-to-NOAEL uncertainty factor).

EPA Response: This is also addressed by responses to external peer reviewer comments under Charge Questions 3a and 4. Due to the uncertainties, EPA declines to use BMD results for female mouse hyperplasia from NTP (2008). Appendix D.1.1 presents the BMD modeling alternatives. The primary reason for the high uncertainty on the BMD estimate is that the hyperplasia response rate at the lowest dose (38%) was much higher than the BMR of 10% ER (the control group had 0% response). The LOAEL divided by a UF_L_ = 10 (the LOAEL-to-NOAEL uncertainty factor) produces a reasonable result when compared with the alternative BMDL_10_s. The value (0.0302 mg/kg-day) is within the bounds of the BMD modeling alternatives: at a BMR of 10%, LOAEL/10 is significantly higher than log-probit, 13% higher than dichotomous Hill, and 43% lower than log-logistic. See Section 4.1.5.6 (“Uncertainty in Dose-response Modeling”) for details. EPA’s LOAEL-to-NOAEL approach for diffuse epithelial hyperplasia of the female mouse duodenum was supported by a majority of the external peer review committee. The final SAB report can be found here (https://sab.epa.gov/ords/sab/f?p=100:0:9977951253767:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1121).

## G.5 CHARGE QUESTION 6 - CARCINOGENICITY HAZARD IDENTIFICATION AND TOXICITY VALUE DERIVATION

[underlined: For each cancer-related health effect and decision outlined below], please comment on whether the available data have been clearly and appropriately synthesized to describe the strengths and limitations and to support the conclusions presented. For each, please also comment on whether the weight-of-evidence decisions for hazard identification have been clearly described and scientifically justified. In addition, please separately comment on whether the dose-response decisions are transparent and scientifically justified, including study selection for dose-response analyses; point of departure (POD) estimates, including modeling choices and assumptions, and dosimetric adjustments; derivation of candidate values; and confidence in the calculated values.

a. EPA concluded that a mutagenic MOA for Cr(VI) carcinogenicity is “sufficiently supported in (laboratory) animals” and “relevant to humans.” The determination applies to both oral and inhalation exposures. For inhalation, there was consistent evidence from humans exposed occupationally. For the oral route of exposure, the small evidence base of low confidence animal mutagenicity studies of drinking water exposures was supported by strong evidence of mutagenicity of Cr(VI) in test systems using more direct exposure methods (e.g., i.p. injection, in vitro) and a biologically plausible pharmacokinetic mechanism for Cr(VI) distributing to tumor target tissues and being taken up and reduced intracellularly to induce toxic and genotoxic effects.
b. Because tumors in rodents and humans were observed in (or proximal to) portals of entry where cellular uptake of Cr(VI) may occur prior to detoxification to Cr(III), and because a mutagenic MOA for Cr(VI) carcinogenicity is “sufficiently supported in (laboratory) animals” and “relevant to humans,” EPA applied a low-dose linearity approach for both the oral and inhalation routes of exposure. In the absence of chemical-specific data to evaluate differences in age-specific susceptibility, increased early-life susceptibility to Cr(VI) is assumed and EPA applied age-dependent adjustment factors (ADAFs) in accordance with the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b).
c. EPA concluded that for cancer via the oral route of exposure, Cr(VI) is likely to be carcinogenic to the human GI tract. This conclusion is primarily based on robust evidence of cancer from a high confidence 2-year cancer bioassay conducted by NTP, which showed a statistically significant increase in oral cavity tumors in male and female F344/N rats and small intestine neoplasms in male and female B6C3F1 mice (NTP, 2008).
d. A POD from NTP (2008), a 2-year drinking water bioassay in rodents, was selected to calculate a total lifetime OSF for Cr(VI) of 0.5 (per mg/kg-day) based on increased incidence of adenomas and carcinomas in the small intestine of male and female mice. This value includes application of ADAFs.
e. The inhalation unit risk (IUR) was based on an occupational cohort by (Gibb et al., 2000b; Gibb et al., 2015; Gibb et al., 2020) of chromate production workers at a facility in Baltimore, MD. Cox proportional hazard modeling of cumulative chromium exposure and lung cancer risk (with exposure lagged by 5 years) was used to estimate the POD at the exposure concentration that would cause a 1% extra risk of lung cancer in the U.S. population, resulting in an IUR for Cr(VI) of 2 × 10^−2^ (per μg Cr(VI)/m^3^) (including application of ADAFs).

### G.5.1 External Peer Reviewer Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

Overall, the panel “agreed that the weight-of-evidence decisions for hazard identification (i.e., that Cr(VI) can cause cancer through both the inhalation and oral routes) have been clearly described and scientifically justified.” All panel members agreed that “the carcinogenicity data for the oral route of exposure support the conclusion that Cr(VI) is likely to be carcinogenic to the human GI tract according to the criteria in the EPA (2005a) Guidelines for Cancer Risk Assessment.”

A large majority of the panel (12 of 14 members) agreed that “the evidence that Cr(VI) causes cancer through a mutagenic mode of action (MOA) was sufficiently supported in experimental systems and was relevant to humans.” The panel noted that “while the rationale supporting the conclusion had been clearly stated, there are many additional genotoxicity and mutagenicity studies, particularly from in vitro test systems and in model organisms (other than laboratory rodents), that would substantially strengthen the case for the mutagenic MOA. The panel, therefore, recommends that these studies be added to the draft IRIS assessment,” and recommended a Tier 1 revision to this affect. The panel also noted that “MOA-related sections were clearly organized and that the strengths of the in vivo studies, along with the reasons for their classification as low, moderate, or high confidence, in most cases, were clearly explained.”

The panel agreed that “the dose-response decisions were transparent and recognized that the choice of linear extrapolation to estimate risk in the low dose region for both inhalation and oral exposures was consistent with EPA guidance.” In general, for oral exposures, the panel maintained that “the data had been clearly and appropriately synthesized to describe the strengths and limitations, and that the rationale and weight of evidence for the EPA's conclusion are transparent and scientifically justified. The panel agreed that the 2-year cancer bioassay conducted by NTP is the key available study,” and the majority of the panel “agreed with the selection of the study, endpoint, approach, and POD used by the EPA to calculate low dose risks of Cr(VI).” However, the panel also noted, “particularly for oral exposures, that there were multiple toxicokinetic factors that could significantly affect the shape of the dose response curve in the low to ultra-low dose region; and therefore, additional evaluation of these factors is warranted,” a comment reflected in a Tier 1 revision recommendation.

The panel agreed that the available data for the IUR “have been appropriately synthesized to describe the strengths and limitations and do support the conclusions presented. The search parameters are defined, and the process used to narrow the choice to one cohort was logical, rational, and carefully explained in detail. Further, the strengths and limitations of the top two choices (i.e., Baltimore, Maryland and Painesville, Ohio) for deriving the IUR are carefully and robustly delineated,” and “how the weight-of-evidence/quality-of-evidence decisions lead to the top choice (Baltimore, Maryland) for deriving the IUR were clearly described and scientifically justified.” In addition, the panel noted that “the dose-related decisions are transparent and scientifically justified, including study selection for dose-response analyses, point of departure (POD) estimates, modeling choices and assumptions, dosimetric adjustments, derivation of candidate values, and confidence in the calculated values.” However, some panel members raised concerns regarding “whether there could be an interaction between Cr(VI) exposure and smoking,” and noted that "the inclusion of studies where the prevalence of smoking is much lower would be beneficial,” citing a new study (Behrens et al., 2023), which is noted in a Tier 2 suggestion. The Tier 1 and 2 comments are further described below.

#### G.5.1.1 Tier 1 Recommendations

SAB Comment: The EPA should include additional genotoxicity and mutagenicity studies, particularly from in vitro test systems and in model organisms (other than laboratory rodents), that would substantially strengthen the case for the mutagenic MOA. More emphasis on Cr(VI)-specific genotoxic effects, such as Cr-DNA adducts and crosslinks, would also strengthen the case for the mutagenic MOA.

EPA Response: Detailed information on genotoxicity was located in the Supplemental Materials of the Toxicological Review (see Appendix C.3.2.1, Electrophilicity and DNA Reactivity (KC#1)). In response to this comment, EPA has moved the detailed discussion of DNA reactivity and the biological effects of Cr-DNA interactions into the main document (see Section 3.2.3.4, MOA Integration of Evidence for Carcinogenesis). In addition, several tables of bacterial mutagenicity assays (Ames tests) and in vitro genotoxicity tests in human and other mammalian cells and cell lines have been added to Appendix C.3.2.2.

SAB Comment: The majority of the panel recommended that the EPA further consider using toxicokinetic factors (specifically, dose-dependency in chromium accumulation) in low dose extrapolation for the oral route of exposure.

EPA Response: Please see the comprehensive response to the comment in Section G.3.1 under Charge Question 4. EPA concludes that other suggested mechanisms of PK nonlinearity are not scientifically consistent with the molecular kinetics of diffusion and transporter-mediated uptake, but also that the gastric PBPK model adequately addresses the observed nonlinearity in intestinal tissue dose. EPA has now revised its analysis of intestinal tumors to fully account for the nonlinearity predicted by the PBPK model. Hence, the analysis now fully incorporates the toxicokinetic nonlinearity in gastric reduction with extrapolation conducted at a dose low enough to account for that nonlinearity.

#### G.5.1.2 Tier 2 Suggestions

SAB Comment: The panel observed that age-dependent exposure to different media such as soil and water should be incorporated into the application of ADAFs when health-based criteria for such specific media are developed.

EPA Response: EPA has, in rare instances (e.g., the TCE IRIS assessment), provided examples outlining how the ADAFs can be applied to constant exposure levels in drinking water over the course of a lifetime that account for changes in drinking water consumption with age. However, such examples run the risk of appearing to be recommendations to risk assessors in EPA Program or Regional Offices, who may have different default age-specific uptake rates that they use for risk assessments for specific exposure scenarios (such as incidental soil ingestion). Given that IRIS assessments do not include exposure assessment or risk characterization, EPA has declined to add these calculations to the Cr(VI) toxicological review.

SAB Comment: The panel recommends that studies be included where the prevalence of smoking is much lower (e.g., Behrens et al., 2023) as it would be beneficial to strengthening the EPA’s conclusions.

EPA Response: Behrens et al. (2023) found that Cr(VI) exposure increased lung cancer risks even among “never smokers.” This finding supports the assumption that effects of chromium exposures occur independently of the effects of smoking. As recommended by the SAB, EPA now cites this additional evidence in Section 4.4.5.7 (“Uncertainty Due to Potential Effect Modification”).

Behrens et al. (2023) was included in the qualitative discussion of uncertainties related to smoking, but it was not preferred for quantitative derivation of IUR for Cr(VI) for the following reasons related to exposure:

1) The assigned exposure concentrations in Behrens et al. (2023) were for job categories and did not necessarily correspond to a particular worker job history. Furthermore, the assigned exposure concentrations were largely based on job- and country-specific measurements of Total Cr in air with an assumption that the ratio of Total Cr was 3:1. These factors create potential bias and uncertainty compared with the exposure measurements for the Baltimore plant analysis.
2) There was very little contrast between the lowest and highest exposure levels because of co-exposures to other industrial chemicals [1.2 × 10^−3^ mg/m^3^ lowest mean exposure vs. 1.5 × 10^−3^ mg/m^3^ highest mean exposure in 1980; see Table 4 of Peters et al. (2016)]. The lack of contrast may be a reflection of the aforementioned potential sources of bias and uncertainty in the exposure measurements.
3) There was significant exposure to asbestos [Table 3 of Peters et al. (2016)] in the SYNERGY cohort, and there was a significant (for men only) adjusted OR for asbestos (about 1.3 for men and 1.1 for women) Olsson et al. (2017), but exposure to asbestos was not accounted in Behrens et al. (2023).

#### G.5.1.3 Other Comments

SAB Comment: The panel recommended that EPA should provide additional information on their rationale for choosing the mouse dataset (i.e., adenomas and carcinomas in the small intestine of male and female mice) as most representative of the overall dose-response in humans.

EPA Response: As there are no data to support any one tumor type (rat oral cavity or mouse small intestine) as most relevant for extrapolating to humans, the most sensitive result for GI tract tumors was used to derive the oral slope factor. This statement has been added to the cancer dose-response section.

SAB Comment: Several detailed comments in Appendix B of the peer review report referred to the draft EPA “Framework for Determining a Mutagenic Mode of Action for Carcinogenicity” (U.S. EPA, 2007) in the context of describing the weight of evidence for a mutagenic MOA for Cr(VI), with the suggestion that had the IRIS assessment followed this framework, a mutagenic MOA would not have been supported; for example, “Reasonable scientific guidance for establishing a mutagenic MOA (EPA 2007, TCEQ 2015) does not support a mutagenic MOA for carcinogenicity having been demonstrated, particularly for the oral route.”

EPA Response: Mccarroll et al. (2010), one of several manuscripts developed as case studies to demonstrate the use of the EPA draft mutagenic MOA guidance, presents a weight-of-evidence analysis using the framework presented in U.S. EPA (2007) that supports a mutagenic MOA for oral exposures to Cr(VI).

### G.5.2 Public Comments on Carcinogenicity Hazard Identification and Toxicity Value Derivation

Multiple public comments: Several commenters disagreed with the proposed mutagenic MOA and the use of linear low-dose extrapolation and ADAFs. The commenters claim that EPA failed to seriously consider state-of-the-art MOA research and the plausibility of a non-mutagenic MOA for Cr(VI)-induced tumors in the small intestine, and that EPA ignored evidence for thresholds in the NTP (2008) cancer bioassay. Multiple public commenters suggested that a nonlinear threshold approach using a reference value be applied to the oral cancer dose-response. Other commenters supported EPA’s determination of a mutagenic MOA and human cancer determination and dose-response analysis. One commenter stated that EPA’s conclusions regarding carcinogenicity of Cr(VI) by the oral route of exposure are well-supported, and that EPA’s draft assessment presents a careful review of the evidence regarding carcinogenicity of Cr(VI) from oral exposures (including extensive discussion of genotoxicity evidence and the MOA analysis). Another commenter states that IRIS took an organized and rational approach of grouping relevant studies according to the 10 key characteristics of carcinogens, and that IRIS did assess the biological plausibility of an alternative MOA (i.e., cytotoxicity and regenerative proliferation).

EPA Response: The majority of the SAB CAAC panel agreed with EPA’s scientific conclusions, including the mutagenic MOA for carcinogenicity, linear low-dose extrapolation, and application of ADAFs.

Public Comment: Several public comments were received that claimed EPA’s Cr(VI) IRIS Assessment is not consistent with other authoritative bodies that have concluded that threshold-based safety criteria are protective against both cancer and noncancer health effects. These commenters stated that the conclusions of other regulatory authorities in Canada, Japan, Texas, and at the World Health Organization (WHO) determined that the MOA evidence supports a cytotoxicity/regenerative hyperplasia MOA more strongly than a mutagenic MOA.

EPA Response: While there may be a lack of consensus among international regulatory authorities that have assessed the risks from Cr(VI) exposures, including among branches of the WHO (summarized in a new Appendix Table B-4), there is a general consensus among U.S. state and federal agencies on acknowledging the genotoxic and mutagenic effects of Cr(VI).

U.S. state environmental agencies that have conducted evaluations of the health effects associated with Cr(VI) have recommended or implemented a linear no-threshold approach for estimating risk from Cr(VI) exposures, including California (CalEPA, 2011), New Jersey (NJ DEP, 2009), North Carolina (Augspurger et al., 2020), and Texas, although for their assessment of inhaled particulate Cr(VI) compounds (TCEQ, 2014); the TCEQ dose-response assessment for oral exposures did select a non-linear threshold approach (TCEQ, 2016). In addition, other U.S. federal agencies assessing risks from Cr(VI) exposure have acknowledged the primary role of genotoxicity for cancer MOA (OSHA, 2006b; NIOSH, 2013; ATSDR, 2012), and EPA’s Office of Pesticide Programs determined a mutagenic MOA in their Report of the Cancer Assessment Review Committee for Cr(VI) (U.S. EPA, 2009).

The majority of the SAB CAAC panel agreed with EPA’s scientific conclusions, including the mutagenic MOA for carcinogenicity (Charge Question 6a) and a linear low-dose extrapolation with application of ADAFs (Charge Question 6b). EPA has responded to all Tier 1 and Tier 2 panel comments.

Multiple public comments: Several comments were received from two commenters who disagreed with EPA’s interpretation of histopathological data of the gastrointestinal tract of rodents for the syntheses of noncancer and cancer GI tract health effects and cancer MOA. These comments are summarized below but are relevant to both Charge Questions 3 and 6. The noncancer synthesis of gastrointestinal tract effects and the cancer MOA analysis were supported by a majority of the external peer review committee. The final SAB report can be found here (https://sab.epa.gov/ords/sab/f?p=100:0:9977951253767:APPLICATION_PROCESS=REPORT_DOC:::REPORT_ID:1121).

Public Comment: One commenter objected to the EPA description of the NTP bioassay as a comprehensive pathology report and the subsequent reanalysis of the NTP histopathology evidence by Cullen et al. (2016) as a hypothesis-driven analysis, stating that “for clarity, the Southern Research Institute pathologists scoring H&E sections in Thompson et al. (2012) and Drs. John Cullen and Jerrold Ward, who re-evaluated the NTP (2007, 2008) and Thompson (2011, 2012) studies had no particular hypothesis about the MOA of Cr(VI).”

EPA Response: The studies by Thompson et al. (2011b); (2012c), which were originally “conducted to investigate the mode of action (MOA) of Cr(VI) in the rodent small intestine” (Cullen et al., 2015), found evidence of intestinal lesions in the rat small intestine, lesions that were not observed in NTP (2008). The stated objective of Cullen et al. (2015) was therefore “to review the duodenal lesions and determine if there were any differences in duodenal lesions in mice and rats and differences between the NTP and Thompson et al. Cr(VI) studies.” The NTP 2-year rodent bioassays are, by comparison, comprehensive evaluations of the effects of a chemical with the objective of identifying all potential toxic and carcinogenic hazards.

Public Comment: The same commenter noted that the re-evaluation of the NTP evidence in Cullen et al. (2015) “found evidence for mild cytotoxicity and regenerative hyperplasia in rat duodenum from NTP studies (Cullen et al., 2016)” where the NTP did not, and states “therefore, NTP may not have extensive experience grading the severity of intestinal lesions.”

EPA Response: One of the two pathologists that conducted the re-evaluation by Cullen et al. (2015) (which reported evidence of intestinal lesions in rats, where NTP did not, when analyzing a subset of the same histopathology slides), John M. Cullen, was one of the pathologists on the NTP Pathology Working Group (PWG) that previously concluded there were no treatment-related, nonneoplastic lesions of the duodenal mucosa in the rat in the 2-year Cr(VI) drinking water bioassay (NTP, 2008). As stated in the NTP report for Cr(VI), “final diagnoses for reviewed lesions represent a [underlined: consensus] [emphasis added] between the laboratory pathologist, reviewing pathologist(s), and the PWG” (NTP, 2008). The review procedures by the NTP PWG, which consists of up to 12 pathologists experienced in rodent toxicologic pathology that reach consensus conclusions on effects using standardized diagnostic criteria, are considered the gold standard in pathology evaluation and peer review [e.g., (Dagli et al., 2019)].

Public Comment: One commenter stated that “EPA fails to mention that the Thompson et al. (2012) study was conducted at the same laboratory (Southern Research Institute, Birmingham, AL) where NTP conducted their Cr(VI) studies.”

EPA Response: The HAWC study evaluation for the mouse bioassay by Thompson et al. (2011b) notes that "study design intended to be identical to NTP bioassays (2007; 2008) for Cr(VI), conducted at same facility (SRI)." This clarification has been added to Section 3.2.2.2 to describe both the mouse and rat studies by (Thompson et al., 2011b; 2012c).

Public Comment: One commenter noted that EPA made unsupported claims throughout the assessment that the severity of diffuse epithelial hyperplasia did not increase with dose, and that this supported a mutagenic MOA, even though this lack of an increase in severity did not prevent EPA from using this endpoint for their RfD.

EPA Response: The severity of diffuse hyperplastic lesions in the duodenal epithelium of mice in the NTP 2-year bioassay (NTP, 2008), which averaged from minimal (severity grade 1) to mild (severity grade 2) in all exposed animals, and appeared to slightly increase only in the highest dose group of female mice, was not factored into the integration of evidence conclusions for noncancer health effects of the GI tract, nor was it considered a major factor in the cancer MOA analysis where regenerative hyperplasia is considered a key event. Therefore, language noting the lack of increases in severity as a potential inconsistency in the discussion of evidence of hyperplasia in Cr(VI)-induced cancer (see Section 3.2.3.4, “Regenerative hyperplasia” and “Cancer mode-of-action summary”) has been removed.

Public Comments: Several comments from two sources were received on EPA’s interpretation of the mitotic index results reported in O'Brien et al. (2013) and Thompson et al. (2015b), and that EPA incorrectly concluded that a lack of change in the mitotic index in small intestinal crypt epithelial cells in mice does not support the evidence that regenerative hyperplasia was occurring in these animals following oral exposures to Cr(VI) in drinking water.

EPA Response: The assessment determines that cytotoxicity and regenerative cell proliferation of the small intestine occur in mice following oral exposure to Cr(VI). The evidence from animals was judged to be robust (see Section 3.2.2.4) and forms the basis of the oral toxicity reference value (RfD, based on small intestine hyperplasia in female rats exposed for two years in drinking water, see Section 4.1). Cytotoxicity and regenerative cell proliferation were also considered to be key events in the pathway to carcinogenesis. The evidence profile table for GI effects and the key events for the cancer MOA summary tables (see Tables 3-21 and 3-22) lays out the evidence used to reach these hazard conclusions, including factors that increase and decrease certainty. The evidence for the increasing size of the intestinal crypts and the number of cells is based on histological findings and is considered biologically plausible.

The draft assessment mentioned the apparent discrepancy in the lack of detection of increases in mitotic indices in tissues with concurrent hyperplasia in O'Brien et al. (2013) and Thompson et al. (2015b), two follow-up publications to Thompson et al. (2011b) conducting additional analyses on the same experimental data. This observation was made by the study authors themselves. O'Brien et al. (2013) states “the lack of a change in crypt apoptotic and mitotic indices indicates that Cr(VI) was not cytotoxic to crypt enterocytes,” indicating that cytotoxicity and compensatory cell proliferation were not evident in the crypts evaluated. The reported lack of changes in mitotic indices in these two studies was not used in the assessment to draw conclusions regarding the occurrence of hyperplasia, but rather was one of several factors that led to overall study evaluation judgments of low confidence for the reported mutagenic endpoints in these two studies (see HAWC for more details). The Cr(VI) assessment has been edited to make it clear that these potentially discrepant findings are noted but did not factor into the evidence integration for hyperplasia.

The observation by EPA is not without precedent. A recent review of the independent peer reviews convened by TERA^13^ in 2012 on two manuscripts prior to publication by this group found that two of seven reviewers of Thompson et al. (2013) in TERA (2012a) and one of four reviewers of O'Brien et al. (2013) in TERA (2012b) also noted the potential discrepancy of hyperplasia without concurrent increases in mitotic figures. In the resulting MOA paper, a potential explanation given is that either the number of crypt basal stem cells has increased or the number of cell divisions in transit-amplifying cells higher up the crypt has increased (Thompson et al., 2013).

Public Comment: Comments related to mitotic indices noted apparent confusion by EPA on interpretations between rate and number of mitotic cells.

EPA Response: As noted above, the assessment mentions the apparent discrepancy in the lack of detection of increases in mitotic indices in tissues with concurrent hyperplasia. The later publication presents a potential explanation of this finding:

“We previously reported that a significant increase in crypt length and enterocyte number following Cr(VI) exposure occurred without a statistically significant increase in mitotic index—despite increased expression of genes (e.g., Ki67) involved in cell proliferation. This apparent contradiction is likely explained by the overall increase in the number of crypt enterocytes, which begin to differentiate as they migrate from the stem cell zone through the transit amplifying region toward the crypt-villus junction. In fact, there are several cell positions near the top of the crypt that have been described as “post-mitotic” maturing regions. When we instead characterize mitotic activity as the total number of mitotic figures per crypt (M/Crypt), there is a significant treatment-related increase after 90 days of exposure (Fig. S3). Thus, when there is obvious crypt hyperplasia, M/Crypt is a more appropriate measure of mitotic activity than mitotic index” (Thompson et al., 2015b).

In other words, this group switched their method for measuring proliferation in the same data two years later, from using the mitotic index (i.e., the ratio of cells undergoing mitosis to those not) per crypt in O'Brien et al. (2013), which detected no increase in mitotic rate, to reporting the mitotic count (i.e., total number of cells undergoing mitosis) cells per crypt in Thompson et al. (2015b), which did show an increase with dose. This latter measure seems appropriate given the fixed area of the crypts. However, it does cause confusion when data are republished with a different analysis giving a different outcome in a different paper. Moreover, the data republished data were presented in a bar chart in the supplemental information with no numeric data. Additionally, the 7-day exposure study reported in Thompson et al. (2015b) did not show an increase in mitotic counts per crypt despite using the updated measure of M/Crypt instead of MI. These distinctions have been clarified in Section 3.2.2.2.

Public Comment: One commenter stated that morphometric evaluations are more appropriate than labeling indices or mitotic indices for rapidly proliferating tissues, citing Wood et al. (2015).

EPA Response: Wood et al. (2015) is a helpful publication by the Society of Toxicologic Pathology Working Group that reviews the methods for measuring cell proliferation and the interpretation of these data in cancer risk assessment. As noted by the commenter, an author on the studies that used mitotic index as a measure of cell proliferation, the paper states that morphometric evaluations of crypt size may be more sensitive for detecting cell proliferation in rapidly proliferating intestinal epithelial cells, and that labeling indices may be similar in untreated and treated intestinal tissues even as the crypts are clearly expanding in size. EPA never disputes that the crypts are enlarged and that this is evidence for proliferation in the small intestine, but this means that increases in mitotic indices should have been observed as well, since this is also a morphometric measure.

Public Comment: Multiple commenters disagreed with the methods and organizational concepts used in the cancer MOA analysis. Commenters claim that EPA inappropriately used the key characteristics of carcinogens as an MOA framework and inaccurately identified key events as MOAs or used multiple terms interchangeably (e.g., MOA, AOP, hallmarks of cancer, key characteristics).

EPA Response: The key characteristics of carcinogens are an organizational construct and not an MOA framework. The key characteristics of carcinogens were used in the assessment to organize and summarize mechanistic evidence relevant to cancer, enabling the identification of key events for Cr(VI)-induced carcinogenesis as a step in conducting an MOA analysis using the 2005 EPA Cancer Guidelines MOA framework, as described in the IRIS Handbook. Section 3.2.3.4 and Table 3-21 of the assessment summarize the evidence for the key events for Cr(VI)-induced carcinogenesis. These key mechanistic events are not described as MOAs. The Cr(VI) assessment identifies where these key events align with the hallmarks of cancer and clearly labels these (where applicable) in a figure that summarizes hypothesized mechanistic pathways connecting the key events (i.e., Figure 3-16).

Public Comment: One commenter suggests EPA use the IPCS MOA/human relevance framework (HRF) for the MOA analyses.

EPA Response: As mentioned in the responses to peer-reviewer comments in Section G.1.1, the MOA frameworks listed in Appendix A of the SAB Report have generally consistent approaches, making it unlikely that the addition of other frameworks to the supplemental materials would have an impact on the MOA conclusions. For example, the IPCS MOA human relevance framework referred to in Appendix A (IPCS, 2007; Boobis et al., 2006) and in extended comments in Appendix B of the peer review report (Charge Question #6a) was implemented in the IPCS Concise International Chemical Assessment Document (CICAD) 78 for Cr(VI) (IPCS, 2013), which concluded that there was no need to consider the MOA for lung cancer due to the availability of epidemiology studies, and that there was no basis for excluding the human relevance of the animal evidence for oral and intestinal cancers due to the cross-species applicability of the evidence of genotoxicity from exposures to Cr(VI) (see Appendix Table B-4). Thus, use of the IPCS framework instead of the EPA cancer guidelines (U.S. EPA, 2005a) would be unlikely to change the overall conclusions in the IRIS toxicological review.

Public Comment: Another commenter said EPA indiscriminately cites some published MOA analyses and not others.

EPA Response: Existing MOA analyses are considered during scoping and problem formulation, but unless otherwise noted in the IRIS assessment protocol, all reviews and studies with no primary data are considered as supplemental materials and tracked in HERO. Thus, MOA analysis review papers or other agency assessments were not cited in the Cr(VI) assessment unless there is a specific reason; for example, the MOA publication by Thompson et al. (2013) was cited in the assessment because Ki-67 data from the Kopec et al. (2012a) analysis was only available (presented graphically) in that publication.

Public Comment: One public commenter stated that the MOA for Cr(VI)-induced small intestinal tumors in mice is the same as that previously shown for captan and folpet, two pesticides that have been evaluated by EPA. An external peer review commenter recommended that literature on other agents (such as captan and folpet) should also be included for purposes of analogy.

EPA Response: While analogy approaches, which rely on predicting the toxicity of chemicals using structural analogues with similar toxicodynamic and toxicokinetic properties, can be useful for data-poor chemicals [see, for example, Lizarraga et al. (2023)], this was considered unnecessary for estimating the hazard identification or dose-response for Cr(VI) exposures. There is a broad evidence base for the toxic effects of Cr(VI), including genotoxicity. Captan and folpet are not chemical analogues of the element chromium and do not share any chemical or toxicological similarities with Cr(VI) except for the induction of hyperplasia and tumors of the duodenum in mice. Chromium is a chemical element and a metal, captan and folpet are not. Cr(VI) induces tumors in the rat oral cavity, captan and folpet do not. The pharmacokinetics and pharmacodynamics are also different. The toxic moiety of captan and folpet (thiophosgene) is short-lived, whereas intracellular Cr(III)-DNA adducts (a product of intracellular Cr(VI) reduction) are not.

Public Comment: Several commenters disagreed with the risk of bias determinations on some MOA studies (i.e., the in vivo mutation studies that were classified as ‘low confidence’ for certain endpoints due to administered or target tissue dose). The commenters believe that EPA incorrectly concluded that the concentrations used in several in vivo target tissue genotoxicity studies were too low to inform MOA, leading EPA to minimize the importance of these genotoxicity findings in MOA consideration. This was due to EPA inappropriately evaluating genotoxicity studies designed to examine the MOA using criteria developed for assessing risk of bias in studies informing hazard identification. Specifically, the consideration of whether an in vivo genotoxicity study included maximum tolerated doses (MTDs), maximum feasible doses, or doses toxic to target tissue, which erroneously led to low confidence judgments for these MOA studies.

EPA Response: There are two related factors involved in the consideration of MTD when evaluating the sensitivity of genotoxicity studies. One is pharmacokinetics: in the absence of inclusion of an MTD in a study with negative results, is there other evidence that the test article reached the target tissue? In the case of the two studies referred to by the commenters (Thompson et al., 2015b; O'Brien et al., 2013), the aim was to investigate the incidence of mutagenic endpoints and a hypothesized non-mutagenic MOA in the mouse small intestine by exposing animals to doses of Cr(VI) in drinking water (at acute or subchronic durations) that were previously shown to cause tumors in this organ in the NTP 2-year bioassay (NTP, 2008). By conducting studies in the tumor target tissues of mice and rats exposed to the same doses in drinking water as the NTP 2-year bioassay (NTP, 2008) and taking measurements at earlier timepoints, the study could assume that the ingested Cr(VI) would reach the target tissues at sufficient levels to cause mutation if it was occurring, since these same doses also caused tumors after two years. EPA does not find fault with this assumption.

The second factor is internal study validity: was the test design sufficiently sensitive to detect an effect, if present? The inclusion of an MTD is one of many factors considered when assessing the sensitivity of the endpoint to detect an effect. For the same two studies, there were several limitations in study design and conduct that made the use of the low dose range in these studies problematic. The micronucleus assays were performed in a nonstandard tissue type (small intestine), with no established laboratory record of historical controls or background incidence of micronuclei, conducted in laboratories that had not previously demonstrated reproducible results for micronucleus frequencies in this tissue with a minimum of two positive controls (OECD, 2016), and, for one of the studies, with no concurrent positive controls. Importantly, these studies reported negative results. If an MTD had been included in these studies, as specifically recommended by the OECD Test Guidelines 474 (OECD, 2016), the toxic levels would have likely induced secondary genetic damage, serving as an internal positive control and establishing confidence that the null findings at lower doses are genuine even though no concurrent positive control was used (or, as was the case in Thompson et al. (2015b), a positive control failed).

This is particularly true for null findings. It is not the relevance of the dose to the proposed MOA that is in question, but the reliability of the study itself. Negative results, in which the study animals do not exhibit evidence of genotoxicity, do not necessarily imply that a test article is not genotoxic, but only that the test article is not genotoxic under those specific conditions. For any study reporting mutagenic testing, there are controls identified by OECD to ensure the results can be interpreted with confidence. If an MTD had been included in these studies, the confidence would have been higher that the null results truly represent an absence of genetic damage at lower doses. However, it was the combination of these errors in study design and concerns regarding internal validity, and not the omission of an MTD alone, that led to the overall study rating of low confidence in these studies.

Other genotoxicity studies conducted in peripheral blood and bone marrow, which are standardized tissues for mutagenic endpoints, also received lower confidence ratings if they did not include an MTD to assist in interpreting negative results. However, for these tissues, there was less certainty that Cr(VI) ingested in drinking water was able to reach the target tissue in sufficient quantities for this to be a sensitive measure of genotoxicity. Because the bioavailability of unreduced Cr(VI) not taken up by red blood cells is expected to be low in circulating blood and bone marrow, the results using traditional genotoxicity testing in these tissues are unlikely to be positive or to even enable an MTD to be reached. Thus, these studies had low confidence ratings primarily due to a lower sensitivity for studies in these tissues to reliably measure an effect if one were present due to the pharmacokinetics of ingested Cr(VI). The lower sensitivity in these tissues was reflected in the inability of these studies to reach an MTD, but the lower confidence rating was due to the lower sensitivity and not specifically to the lack of an MTD. One study, Shindo et al. (1989), did include an MTD as shown by the inclusion of an acutely toxic dose that reduced the PCE/NCE ratio >50%, but this study was found to be low confidence for reporting deficiencies. It is likely the MTD was only possible in this study in mouse bone marrow because a gavage dose was used, resulting in a significantly higher internal dose than drinking water exposures.

The study evaluations for all animal studies reporting mutagenic endpoints have been revised to describe the inclusion of an MTD as one of many factors considered when assessing the sensitivity of the endpoint to detect an effect and therefore only affects the sensitivity domain. The assessment has been edited to make this distinction clear, and to remove discussion of MTD if not directly related to the sensitivity of the study.

Public Comment: One commenter objected to the discussion of Cr(VI)-induced suppression of CFTR and the potential susceptibility of carriers of the mutated CFTR allele to Cr(VI) exposures because there is no evidence that CFTR is a tumor suppressor gene or that CFTR inactivation is involved in gastrointestinal tract tumors in exposed animals or humans.

EPA Response: Tumorigenesis is a complex process. Predictions implicating the roles of specific genes in cancer are appropriate for suggesting possible vulnerable groups for cancer development if the implicated genes enhance cancer risk in susceptible populations by a plausible mechanism. The Cr(VI) assessment does not include inactivation of CFTR as a specific key event for carcinogenesis, but rather summarizes the growing body of evidence supporting a tumor-suppressor role of the CFTR gene, which a recent analysis has shown to be suppressed in animals exposed to Cr(VI) (Mezencev and Auerbach, 2021). Several studies have demonstrated a tumor suppressor role for CFTR, including significantly increased formation of tumors in the colon and small intestine of CFTR knockout mice (Than et al., 2016); significantly increased colon organoid formation in organoids created from CFTR mutant mice compared with wild-type controls, suggesting a potential role of CFTR in regulating the intestinal stem cell compartment (Than et al., 2016); and the inhibition of migration, invasion, and proliferation of colon cancer HCT116 and CaCo-2 cell lines with CFTR overexpression (Liu et al., 2020). Of note, epidemiological data indicate that, at least for some cancers, CFTR impairment can contribute to carcinogenic risk. This has been observed in cystic fibrosis (CF) carriers (i.e., people with one pathogenic allele of CFTR), where the deficit in CFTR function has been shown to lead to an increased risk for several conditions associated with the disease, including colorectal cancer (OR = 1.44, 95% CI: 1.01–2.05) (Miller et al., 2020). Consequently, these carriers, who already experience a diminished function of CFTR, would be highly susceptible to any further suppression of CFTR that would further increase these risks. There are estimated to be 10 million carriers of a mutated CFTR allele in the US alone (Scott et al., 2020). Therefore, evidence that Cr(VI) can suppress CFTR function is relevant to discussions of potential susceptibilities to the carcinogenic effects of Cr(VI) exposures in humans.

Public Comment: One commenter stated that IRIS’s assessment of the epidemiology of oral exposure to chromium is also seriously flawed. Commenter states EPA did not acknowledge that older studies did not account for confounding by exposure to Helicobacter pylori (the major known cause of stomach cancer in humans), and the older studies EPA refers to were performed prior to accepted knowledge of H. pylori and its routine evaluation in gastric biopsies.

EPA Response: Risk factors for GI tract cancers such as obesity, H. pylori infection, dietary factors and family history of such cancers were not likely to be differentially associated with chromium-exposed occupations or jobs and thus any differences would be expected to be random. In the GI tract cancer integration of evidence in the draft assessment, EPA concluded the “evidence of carcinogenicity of the GI tract from human studies is slight based on studies of the oral route of exposure” due to uncertainties in study methods and analyses.

Public Comment: One commenter stated that the Baltimore cohort had multiple data limitations, and that additional information from newer research should be used to derive the IUR. Data limitations focused on exposure concentrations and low-dose extrapolation, potential confounders (smoking, asbestos), chemical form of chromium, and population diversity. Another commenter disagrees with the IUR derivation and proposes other less-stringent linear analyses or threshold analyses that have been published.

EPA Response: EPA considered these comments, which were also available to the SAB peer reviewers. The peer reviewers agreed that the choice of Baltimore (Gibb) cohort was “clearly described and scientifically justified.” The dose-response analyses used to derive the IUR were supported by a majority of the external peer review committee. EPA’s responses to Tier 1 and Tier 2 external peer reviewer comments related to data limitations and confounders for the Baltimore cohort are presented elsewhere in Appendix G.

Public Comment: Multiple commenters stated that there is strong pharmacokinetic evidence against linear risk within typical environmental exposure levels. Commenters stated that EPA’s linear no-threshold cancer slope factor approach was inconsistent with scientific evidence (including PBPK models) indicating that Cr(VI) ingested at environmental levels is reduced to trivalent chromium in the stomach.

EPA Response: EPA has developed new subsections (see Section 3.1.2.2, discussing possible pharmacokinetic mechanisms; Section 4.1.5.7, describing the impact of nonlinearity from an alternate approach for the RfD; and Section 4.3.5.1, describing an alternate analysis of intestinal tumors using tissue doses) assessing potential low-dose nonlinearities in the GI tract. EPA presents data from a human experiment (Donaldson and Barreras, 1966) showing that ingested concentrations of Cr(VI) as low as 0.013 ppb (which is environmentally relevant) would absorb systemically at the same fractional uptake that has been estimated at higher exposures. Please see the comprehensive responses to similar peer-reviewer comments in Section G.3.1 under Charge Question 4.

Public Comment: Multiple commenters were not supportive of EPA’s cancer determinations and stated that the IRIS assessment cannot be used to set regulatory standards under the Safe Drinking Water Act. These commenters were concerned that the IRIS assessment will lead to negative impacts to their industries due to infeasible drinking water regulations, highlighting the technical and financial challenges in reducing concentrations of Cr(VI) in drinking water. Other commenters were supportive of EPA’s cancer determinations. Supportive comments include users of IRIS values and environmental groups and concerned citizens who want Cr(VI) removed from tap water.

EPA Response: Derivation of regulatory standards is outside the scope of IRIS assessments. IRIS assessments are not regulations, but they provide a critical part of the scientific foundation for decisions to protect public health across EPA’s programs and regions under an array of environmental laws (e.g., Clean Air Act, Safe Drinking Water Act, Comprehensive Environmental Response, Compensation, and Liability Act). EPA’s program and regional offices combine information from IRIS assessments with relevant exposure information for a chemical to assess the public health risks of environmental contaminants. EPA decision-makers use these risk assessments, along with other considerations (e.g., statutory, and legal requirements that can include cost-benefit information, technological feasibility, and economic factors) to inform risk management decisions, which can include proposed regulations to protect public health.

Public Comment: Multiple commenters state that the Draft IRIS Assessment is not best available science. One commenter states that the IRIS assessment does not comport with EPA’s Information Quality Act (IQA) Guidelines because the Draft IRIS Assessment is not ‘accurate, reliable, and unbiased’ and does not weigh the evidence properly in reaching conclusions about the human carcinogenic potential of Cr(VI) typical drinking water levels. Multiple commenters stated that the IRIS assessment does not comport with the Guidelines for Carcinogenic Risk Assessment. Multiple public commenters suggested that a nonlinear threshold approach using a reference value be applied to the lung cancer dose-response, or that the age-dependent adjustment factor (ADAF) not be applied.

EPA Response: The Cr(VI) IRIS assessment underwent external peer review in accordance with Information Quality Act Guidelines. To ensure the quality, objectivity, and utility of the information, this IRIS assessment underwent an external peer review by the SAB Chemical Assessment Advisory Committee (CAAC). The SAB was established to review the quality and relevance of the scientific and technical information being used by the EPA or proposed as the basis for Agency regulations. The CAAC provides advice through the chartered SAB on EPA guidance documents, methodologies and assessments that evaluate human health effects resulting from exposure to environmental hazards, as well as selected toxicological reviews. The majority of the SAB CAAC panel agreed with EPA’s scientific conclusions, including the linear low-dose extrapolation and application of ADAFs. EPA has responded to all Tier 1 and Tier 2 panel comments. The final SAB report can be found here.

## G.6 ADDITIONAL COMMENTS

### G.6.1 Editorial Comments^14^ from Appendix A of Science Advisory Board Peer Review Report

SAB Comment: Uninformative studies appear to be displayed in tables for animal studies (e.g., Table 3-6) but not for epidemiological studies (e.g., Table 3-4). EPA should review the draft IRIS assessment for opportunities to present animal and epidemiological literature in a more consistent fashion.

EPA Response: EPA uses the same approach for human and animal studies when presenting study evaluation summaries in tables. Because study evaluations are explicitly conducted at the level of an individual outcome or group of outcomes tested within a matched group (e.g., exposed, and unexposed) of animals or humans, a single study (epidemiological or animal) that reports more than one outcome meeting PECO criteria will have separate confidence ratings for each. If every outcome evaluated in a study is uninformative, that study is not added to the summary table. However, if the ratings from a single study differ, for example, if a study is high confidence for liver enzyme data but also rated uninformative for liver weight, the study is added to the table because of the “H” for liver enzymes but the “U” for liver weight is also added for completeness. In the draft IRIS Cr(VI) assessment, when these studies with more than one outcome were listed in the summary confidence tables, as with Glaser et al. (1986) in Table 3-6, or with Littorin et al. (1983) in Table 3-16, the uninformative outcomes were also listed so that it did not appear as if the study did not report that outcome, while all other studies with only uninformative ratings were listed in a footnote below the table. The complete study evaluation heatmaps with fully described domain ratings for each study are available in HAWC.

SAB Comment: The EPA should not use the phrase “non-statistically significant increases” (p. 3–165, line 15) as it is inappropriate. A parameter cannot be said to increase if it does not significantly differ from the control.

EPA Response: The limitations of sole reliance on statistical significance for reaching conclusions are well recognized (Ziliak, 2011; Sterne et al., 2001; Savitz, 1993; Rothman, 2010; Newman, 2008; Hoenig and Heisey, 2001). Because statistical significance is a function of sample size, an effect’s prevalence, and strength of the association with an exposure, the lack of statistical significance in the presence of an elevated effect estimate often means that chance cannot be ruled out with confidence. A footnote summarizing these points has been placed at the first usage of the term “non-statistically significant.”

SAB Comment: The complete results of the BMD modeling should be included in the draft IRIS assessment Appendix material as a separate chapter.

EPA Response: Complete BMD modeling results for selected endpoints (specifically, diffuse epithelial hyperplasia of male and female mice and small intestinal tumors of male and female mice) have now been included in Appendix D.8. The complete set of BMDS outputs were not included in the appendix due to the large volume of model results that require manual conversion for accessibility compliance, but they are available for download from HERO in their entirety: U.S. EPA (2021a).

SAB Comment: Because there are orders of magnitude differences in the PODs derived using different models that have rather similar statistical parameters, it is challenging to evaluate the selection of “the lowest Akaike's information criterion (AIC)/highest p-value” approach to POD selection without reviewing the complete BMD modeling results, which are needed to determine how well the model fits the data. To improve transparency, the results for the model that was selected as the basis for the POD should also be shown in the main draft IRIS assessment.

EPA Response: EPA has evaluated the BMD models in accordance with the criteria outlined in Appendix D.1.1 and D.2.1. The extensive summary statistics of BMD models are typically not included in the main body of IRIS assessments. Complete BMD modeling results for selected endpoints (specifically: diffuse epithelial hyperplasia of male and female mice, small intestinal tumors of male and female mice) have now been included in Appendix D.8. It was not feasible to include all BMDS outputs in the appendix; they are available for download from HERO: U.S. EPA (2021a).

### G.6.2 Additional Public Comments

Public Comment: Multiple commenters urged the U.S. Environmental Protection Agency (EPA) not to finalize the draft assessment until the agency addresses and corrects deficiencies in its evaluation of key science issues.

EPA Response: To address key scientific issues identified in the Cr(VI) IRIS assessment, EPA has held four public science meetings that included feedback on the key science issues from external experts and has undergone a total of four public comment periods associated with the release of two preliminary material packages (U.S. EPA, 2014b, c), the Cr(VI) protocol (U.S. EPA, 2019b), and the public comment draft, in addition to the external peer review by the SAB Chemical Assessment Advisory Committee (CAAC). The majority of the SAB CAAC panel agreed with EPA’s scientific conclusions, including EPA’s evaluation of key science issues. EPA has responded to all Tier 1 and Tier 2 panel comments. The final SAB report can be found here.

Public Comment: Some comments were received related to chemical speciation and exposure to multiple metals. One commenter noted that Cr(VI) is present in the environment as different compounds, each having different chemical and physical properties. This commenter questioned whether each has been studied and considered, and if one is more prevalent in drinking water than others, whether it should be the basis of maximum contaminant level goals. Another commenter stated that EPA should include discussion of potential groundwater interactions and concentrations of other metal ions. This commenter stated concerns about risk posed by mixtures of metals.

EPA Response: All Cr(VI) compounds are ionized to Cr(VI) in the body and are considered to exert the same pharmacological and toxicological effects. This is stated in Section 1.1.2 of the toxicological review. While consideration of coexposures is not within the scope of this assessment, EPA is more broadly developing approaches for assessing cumulative risk in these scenarios.

Public Comment: NJDEP requested that IRIS correct information regarding NJDEP’s soil remediation criterion as reported in the Supplemental Information document. Specifically, NJDEP requested that the word “suggested” being inserted before “soil remediation criterion…” in the “Risk value or limit” column of the “New Jersey DEP (2009)” row of Table B-3.

EPA Response: This correction has been made.

11 Newly identified studies (i.e., studies identified by EPA or the public that meet PECO criteria but were not addressed in the external review draft, for example due to recent publication) will be characterized by EPA and presented to the peer review panel. This characterization will focus on EPA’s judgment of whether the studies would have a material impact on the conclusions (i.e., identified hazards or toxicity values) in the external review draft. The peer review panel is asked to review EPA’s characterization and provide tiered recommendations to EPA regarding which studies, if any, to incorporate into the assessment before finalizing.

12 As described in the Toxicological Review, the exposure conditions for each identified hazard are further defined through dose-response analyses.

13 Toxicology Excellence for Risk Assessment’s independent peer consultation for hexavalent chromium mode-of-action research: https://tera.org/Peer/Chromium/Chromium.htm

14 All minor editorial comments in Appendix A of the SAB peer-review report have been addressed; only those that required further explanation are discussed here.