# APPENDIX E SAS CODE FOR LIFE-TABLE ANALYSIS

The following pages contain the SAS programs for life-table analysis.

 OPTIONS NODATE NONUMBER orientation=landscape linesize=max; *BT added 7/3/19;
 /*
 This program calculates the risk of lung cancer from inhalation exposure to Cr(VI),
 using a lifetable approach based on BEIR IV. The basic exposure-response model is RR = exp(beta *
 CE5).
 
 The basic code for the lifetable calculations were developed and provided to EPA
 by Randall Smith at NIOSH. The code from NIOSH calculates the baseline risk (R0) and the exposed
 risk (Rx)
 from exposure to an exposure concentration of X_Level using NIOSH Model 1: Rx = R0 * exp(COEF *
 X_Level).
 
 EPA has modified the NIOSH as follows:
 1) The all-cause and cause-specific (lung cancer) mortality data tables have been updated
 2) The equation for calculation of X_Time has been revised so all values are based on mid-point
 of year:
         XTime = min(max(0,(age+0.5-&Age1st_x-&Lag)),&Duration-0.5)
 3) An equation has been added to calculate extra risk: Extra_Risk = (Rx - R0) / ( 1 - R0)
 3) A macro has been added to find the exposure level (X_Level) that yields an extra risk of 0.01
 (1%).
 This is referred to as EC1%, which may then be used to calculate the unit risk: UR = 0.01 / EC1%
 */
 /* .\Beta Version.sas 19jan00, 26jul00, 25oct01, 06dec05, 30nov18
 ----------------------------------------------------------------------------
 Experimental version
 ---------------------------------------------------------------------------- */
 title "Lifetable calculation of lung cancer risk";
 title2 "under a non-linear relative rate model";
 
 /*------------------------------------------------------------------+
 | Compute excess risk by the BEIR IV method using SAS datasteps. |
 |		  |
 | These programs compute the risk of a cause-specific	 |
 | death in the presence of competing risks, where the cause-  |
 | specific death-rate is modeled either as a relative rate   |
 | [h=h0*f(Coef*X)] or as an absolute rate [h=h0+f(Coef*X)]   |
 | where	|
 | h denotes the cause-specific death-rate,	|
 | X denotes cumulative occupational exposure (with Lag) |
 | Coef denotes the coefficient for the effect of exposure and |
 | h0 is the corresponding rate at baseline (X=0).	|
 | (Except for Coef, these are functions of age.)       |
 |		 |
 | A few simple models of f(Coef*X) are easily specified as   |
 | described below. More complicated models can be specified with |
 | a little more work. (For a more complicated example,	  |
 | see \_GENERAL.LIB\PROGRAMS\SAS\BEIR-4.Method\BEIR4ex2.SAS).  |
 |		  |
 +Reference:		 +
 | Health Risks of Radon and Other Internally Deposited Alpha-  |
 | Emitters (BEIR IV). Committee on the Biologic Effects of  |
 | Ionizing Radiations. National Academy Press. Wash. DC (1988). |
 | See especially pages 131-136.		|
 |		  |
 |		  |
 +USER-SUPPLIED ASSIGNMENTS:	     +
 |		  |
 |> The following macro variables are assigned using "%LET" state- |
 | ments: MODEL, COEF, LAG, AGE1ST_X, DURATION, LASTAGE.	|
 | Further information appears below.	|
 |> Exposure concentrations for computing risk are defined	|
 | in the datastep "X_LEVELS."	|
 |> All-cause mortality information is entered as a life-table in |
 | the data step "ALLCAUSE," and converted to rates per individual.|
 |> Cause-specific mortality information for unexposed referents is |
 | entered as rates per 100,000 and converted to rates per	   |
 | individual in the data step "CAUSE."	     |
 |		  |
 |		  |
 
 +NOTES:		     +
 
 |> Datastep "EX_RISK" is where the desired risks are computed. |
 |	|
 |> If the unexposed(referent) cause-specific mortality rate is from|
 | a model then datastep "CAUSE" with variables AGE and RATE as	      |
 | modeled can be modified to incorporate this. However, care        |
 | must be taken in calculating confidence limits since imprecision|
 | in the estimates of all of the parameters of the model	|
 | contributes to the imprecision of excess risk estimates. |
 |		  |
 |> This program is currently set up to apply the Linear Rel. Rate |
 | model (Lag= 0) and accumulation of excess risk is over the |
 | rates in ALLCAUSE and CAUSE unless truncated at a younger age. |
 | (See LASTAGE below.)		|
 |			|
 |			|
 + SAS Programmer: Randall Smith	+
 |     The Nat'l Inst. for Occupational Safety & Health |
 |     26jul2000, 23jul2001, 25oct2001, 18nov2018 |
 + Modifications:	+
 | 26jul00 Fix the procedure bug causing it to report incorrectly |
 |    the age at which accumulation of risk was stopped |
 |    whenever the age-specific rates included ages |
 |    before the value of &Age1st_X. (&Age1st_X is a macro|
 |    expression defining the age exposure begins.) |
 |			|
 | 23jul01 Make changes to facilitate multiple applications of |
 |   BEIR4 algorithm, i.e., MLE(Excess Risk), UCL(ExcessRisk),|
 |   searching for concentrations for a fixed risk. These |
 |   changes involve defining Macros named BEIR4 and SEARCH |
 |   given below with code illustrating these uses for the |
 |   linear relative rate model.	|
 |			|
 | 25oct01 Modified to add Macro variable EnvAdj for whether to |
 |   increase inhaled dose from intermittent occupational |
 |   exposures to continuous environmental exposures	|
 |   and update US rates for Gibb et al. cohort.	|
 |			|
 | 30nov18 A bug that prevented the calculation of excess risks |
 |   after incorporating an adjustment from intermittent |
 |   occupational exposures to continuous exposures is fixed. |
 +---								   |
 | March 2019: BT (SRC) Added maxro CONVERGE_BEIR4 which iteratively |
 | runs macro BEIR4 until the EXPOSURE_CONCENTRATION corresponds to an |
 |extra_risk=0.01 (the point of departure [POD]).
 |
 
 | Macro CONVERGE_BEIR4 works with one value for the exposure	|
 | variable XLevel (i.e., when the data C_Levels includes one record.) |
 |
 			      |
 | The intent was to make as few changes to BEIR4 as possible. The data |
 | X_LEVELS and variable XLevel are retained but the initial value of |
 | XLevel is provided in the call to macro CONVERGE_BEIR4 (the value |
 | of Xlevel in the cards statement is not used in the calculations. |
 | Changes to the BEIR4 macro are in Part III and Part IV, and are |
 | indicated by the letters BT.
 | In addition to the parameter values that are specified by the user |
 | in PART 1, and the user-provided data entered in Part II, parameters |
 | for the new macro CONVERGE_BEIR4 are specified in the call to the |
 | macro CONVERGE_BEIR4 (see end of this SAS program file below). |
 +----------------------------------------------------------------------*/
 
 /* PART I. USER-SUPPLIED ASSIGNMENTS (Macro variables):
  /*-------------------------------------------+
 | Model of cumulative exposure effects:	  |
 |	1 => Loglinear Relative rate |
 |	  R=R0*exp(COEF*X) |
 |	2 => Linear Relative rate, |
 |	  R=R0*(1+COEF*X)	|
 |	3 => Absolute rate,	|
 |	  R=R0+COEF*X	|
 |	4 => Power relative rate |
 |	  R=R0*(1+X)^COEF	|
 |	0 => User Defined & programmed |
 |	  in datastep Ex_Risk below |
 |		*/ %Let Model = 1;
 /*		|
 | Cumulative exposure parameter:	*/ %Let COEF = 0.001298;
 /*		|
 | Lag or delay between exposure and effect: */ %Let Lag = 5;
 /*		|
 | Age exposure begins:	*/ %Let Age1st_x = 16;
 /* Exposure duration (years):	*/ %Let Duration = 85;
 /* Adjust dose from occupational to	|
 | continuous environmental exposures (Y/N)? */ %Let EnvAdj = Yes;
 /* Age to stop accumulating excess risk |
 | (supposing rates are available for |
 | ages >= &LastAge); otherwise use all of |
 | the supplied rate information:	*/ %Let LastAge =85;
 /*-------------------------------------------*/
 
 /* PART II. USER-SUPPLIED ASSIGNMENTS (Datesets AllCause, Cause, X_Levels ): */
 
 data AllCause (label="Unexposeds' age-spec mortality rates (all)" drop=Lx rename=(BLx=Lx) );
 /*-----------------------------------------------------------------+
 | Input lifetable and calculate the corresponding age-specific |
 | (all-causes) mortality rate (AllCause) and conditional survival |
 | probability for each year of age (qi) together with	|
 | the corresponding values of age (Age).	|
 +-----------------------------------------------------------------*/
  Label Age = "Age at start of year (Age=i)"
    BLx = "Number alive at start of year"
    Lx = "Number alive at end of year"
    CndPrDth = "Pr[Death before age i+1 | alive at age i]"
    qi = "Pr[Survive to age i+1 | Alive at age i]"
    AllCause = "Age-spec mortality rate (all causes)";
 
  if _n_=1 then input age //// @1 BLx @; /* //// => skip next 4 lines */
  input Lx @@;
  CndPrDth = (BLx - Lx)/BLx;
 
  qi = 1-CndPrDth;
  if qi <= 0 then AllCause = 1e+50;
     else AllCause = - log(qi);
 
  if age < &LastAge then output; else STOP;
  BLx=Lx;
  age+1;
  retain age BLx;
 cards;
 
   0 = Life-table starting age. (Required: Values must begin 4 lines down!)
    The following are 2017 Life-table values of US population
    starting at birth and ending at age 85.
    (Source: Nat.Vital Statistics Reports 2019 Vol 68 No 7, Table 1,
 https://www.cdc.gov/nchs/data/nvsr/nvsr68/nvsr68_07-508.pdf)
   100000 99422 99384 99360 99341 99326 99312 99299 99288 99278
   99268 99259 99249 99236 99217 99191 99158 99116 99066 99006
   98937 98858 98770 98674 98573 98466 98355 98241 98122 97999
   97872 97740 97603 97461 97314 97163 97006 96843 96674 96501
   96321 96135 95939 95732 95511 95275 95023 94753 94461 94144
   93797 93419 93008 92560 92070 91538 90963 90345 89684 88978
   88226 87424 86570 85664 84706 83696 82632 81507 80315 79048
   77697 76265 74715 73064 71296 69418 67402 65245 62933 60462
   57839 55053 52123 49035 45771 42382
  ;
 *run;*BT 7/3/19 added Run statement here;
  
  data CAUSE (label="Unexposeds' age-cause-spec mortality rates");
  /*---------------------------------------------------------------+
  | Specify unexposeds' age-specific mortality rates (per year) |
  | from specific cause.		  |
  +---------------------------------------------------------------*/
   label Age = "Age"
     Rate_e5 = "Age,cause-specific rate per 100,000"
     Rate = "Age,cause-specific rate per individual";
 
   if _n_ = 1 then input age /* input starting age */
         ///; /* /// => skip next 3 lines */
   input Rate_e5 @@;
 
   Rate = Rate_e5 * 1e-5; /* Convert to rate per individual */
 
   if age <= 4
    then DO; output; age+1; END;
    else DO i = 0,1,2,3,4; /*-----------------------------------------*/
      if age < &LastAge /* Fill out into yearly intervals from */
       then output; /* inputted five year intervals after age 4*/
      age+1;	/*-----------------------------------------*/
     END;
  cards;
  0 = Start age of cause-specific rate (Required: Rates begin 3 lines down!)
    The following are 2017 ICD10 = 113, (C33-C34) death rates per 100,000 for US pop'n starting at
  birth.
     For ages 5 and above, each rate holds for the age thru age+4 years.
 	 Source: CDC Wonder, https://wonder.cdc.gov/ucd-icd10.html
  0 0.038 0.038 0.038 0.038 0.010 0.019 0.033 0.045 0.120 0.382 1.074 3.131 8.506 24.321 54.508
  87.599 131.875 198.108 265.763 309.625
 ;
 *run; *BT 7/3/19 added Run statement here;
  data X_LEVELS (label= "Exposure levels (e.g., concentrations)" );
  /*----------------------------------------------------------------------+
  | Specify environmental exposure levels	|
  | and update label for the variable, XLevel, if necessary:	|
  +----------------------------------------------------------------------*/
  /*---------------------------------------------------------------------+
  | BT 3/8/19: Add maxro CONVERGE_BEIR4 which iteratively runs macro |
  | BEIR4 until the EXPOSURE_CONCENTRATION corresponds to extra_risk=0.01|
         |
  | The intent was to make as few changes to BEIR4 as possible. The data |
  | X_LEVELS and variable XLevel are retained but the initial value of |
  | XLevel is provided in the call to macro CONVERGE_BEIR4 (the value |
  | of Xlevel in the cards statement is not used in the calculations. |
  +----------------------------------------------------------------------*/
    input XLevel @@;
    label XLevel= "Cr(VI) exposure (μg Cr(VI)/m3)";
  cards;
  1
  ;
 run;
 
 %Macro BEIR4;
 /* March 2019 - BT (SRC): Macro BEIR4 is now called by macro CONVERGE_BEIR4.
 */
 /* 23jul01 modification */
 /* Enclose the actual calculations and printed results in a macro */
 /* to facilitate multiple applications of the algorithm.	*/
 
 /* PART III. Perform calculations:	*/
 
  data EX_RISK (label = "Estimated excess risks [Method=BEIR IV]"
      /*keep = XLevel Rx ex_risk RskRatio R0 extra_Risk */
      rename= (Rx=Risk));
 /*---------------------------------------------------------------+
 | Calculate risk and excess risk for each exposure concentration|
 | in work.X_Level by BEIR IV method using information in |
 | work.AllCause and work.Cause to define referent population: |
 +---------------------------------------------------------------*/
               format hi F15.8; *BT 7/3/19: added the format statement;
  length XLevel 8.;
  label Age = "Age at start of year (i)"
    XTime = "Exposure duration midway between i & i+1"
    XDose = "CE5(adj) (μg Cr(VI)/m3-yrs)"
 
    R0 = "Cumulative Risk of lung cancer (unexposed) (R0)"
    Rx = "Cumulative risk of lung cancer (exposed) (Re)"
    Ex_Risk = "Excess risk (Rx-Ro)"
    RskRatio = "Ratio of risks (Rx/Ro)"
    
    hi = "Lung Cancer hazard (unexposed) (hi)"
    hix = "Lung Cancer hazard (exposed) (hei)"
    hstari = "All cause hazard (unexposed) (h*i)"
    hstarix = "All cause hazard (exposed) (he*i)"
   qi = "Probability of surviving year i assuming alive at start (unexposed) (qi)"
    S_1i = "Probability of surviving to end of year i (unexposed) (S1,i)"
    S_1ix = "Probability of surviving to end of yeari (exposed) (Se1,i)";
 
 /* BT 3/8/19: Calculation of unexposed's risk (following DO LOOP) could be omitted from the
 iteration
                               but may require further changes to BEIR4(?).
                *e.g., %if i=1 %then %do;*/
 
          if _n_=1 then DO;
	   /* Calculate unexposed's risk (R0) to be retained	*/
	   /* based on equation 2A-21 (pg. 131) of BEIR IV:	*/

	   /* Initialize: */ S_1i = 1; R0 = 0;
 
	   DO pointer = 1 to min(n_all,n_cause) until (age>=&LastAge-1);
	    set allcause (keep=age AllCause rename=(AllCause=hstari))
	      point=pointer nobs=n_all;
	    set cause (keep=age Rate rename=(age=ageCause Rate=hi))
	      point=pointer nobs=n_cause;

	   if Age NE AgeCause then
          put "** WARNING: Age values in datasets ALLCAUSE and CAUSE don't conform **"
             /  @13 "Rates misaligned on age could give incorrect results"
             /  @13 Pointer=
              +2 "Age(ALLCAUSE)=" Age +2 "Age(CAUSE)=" AgeCause /;

	  qi = exp(-hstari);
          R0 = R0 + ( hi/hstari * S_1i * (1-qi) );
	  S_1i = S_1i * qi;
	END;
       END;	/* End of 'if _n_=1 then DO;' stmt */

       retain R0;
 
 /* Calculate exposed's risk (Rx, renamed to Risk) for each exposure level */
 /* ultimately based on equation 2A-22 (pg. 132) of BEIR IV */
 /* but re-expressed in a form similar to equation 2A-21: */
 
 * BT 3/20/19. This version of CONVERGE_BEIR4 will work when there is one concentration in data
 set x_levels - i.e., one value for xlevel.
		       The Do loop for X_levels is commented out;
		       DO pointX = 1 to No_of_Xs;
 * set x_levels point=pointX nobs=No_of_Xs; /* BT 3/8/19: determines when to end the loop. Nobs is
 set at compilation, so the value of nobs is available at first run through loop - just one
 record and one variable (XLevel) in dataset x_levels. */
 
 /* BT 3/20/19: added the next lint to set the exposure concentration = current value of
 &exposure_conc. */
                                                      xlevel = &exposure_conc;
 
 
		      /* Initialize : */ S_1ix = 1; Rx = 0;S_1i=1; R0=0;
 
		      DO pointer = 1 to min(n_all,n_cause) until (age>=&LastAge-1);
		       set allcause (keep=age AllCause rename=(AllCause=hstari))
                        point=pointer nobs=n_all;
		       set cause (keep=Rate rename=(Rate=hi))
		        point=pointer nobs=n_cause;
 
		      XTime = min( max(0,(age+0.5-&Age1st_x-&Lag))
                         , &Duration - 0.5 );
			 
 if UpCase("&EnvAdj") = "YES"
 /* Occupational to Environmental Conversion */
                     then XDose = XLevel
		        * 365/240 /* Days per year	*/
			* 20/10 /* Ventilation (L) per day */
 /*			 * 1/0.52 Converting Beta(CrO3) to Beta(Cr(VI)) */
 /*			 * 1/1000 Converting mg/m3 to ug/m3 */
                       * XTime;
		   ELSE if UpCase("&EnvAdj") = "NO" /* 30nov2018 ('ELSE') */
		    then XDose = XLevel*XTime;
		    else DO; put //"Macro variable ENVADJ incorrectly specified."
		    /"It should be either YES or NO. Value specified is: &ENVADJ"
		       /;
		      STOP;
		     END;
		   hix=.;
		   if &Model = 1 then hix = hi * exp(&COEF*XDose); else
		   if &Model = 2 then hix = hi * (1 + &COEF*XDose); else
		   if &Model = 3 then hix = hi + &COEF*XDose;	else
		   if &Model = 4 then hix = hi * (1 + XDose)**&COEF; else
		   if &Model = 0 then DO;
		    hix = -99999; /* Code for user-defined model goes here. */
		   END;

		   
		  hstarix = hstari /* hi=backgrd rate is included in hstari */
		    + (hix - hi); /* so that adding in the excess */
		        /* from exposure (hix-hi) gives the */
			/* total rate of the exposed.	*/
		  qix = exp(-hstarix);
		  Rx = Rx + ( hix/hstarix * S_1ix * ( 1-qix ) );
		  S_1ix = S_1ix * qix;
 
			             qi = exp(-hstari);
				     R0 = R0 + ( hi/hstari * S_1i * (1-qi) );
				     S_1i = S_1i * qi;
				     output;
 
	          END;
 
 
 
			     Ex_Risk = Rx - R0;* Rx = risk in exposed population;
	           RskRatio = Rx / R0;	    * R0 = from cancer;
 
			     Extra_risk = Ex_Risk/(1-R0);
 
				    /* BT 3/20/19 added:*/
				    call symput('Extra_Riskm',Extra_Risk);
 
				    /*BT 4/24/19 replaced the next line
				    Diff_Ex_Risk = abs(&ex_risk_target-Ex_Risk); */
				    Diff_Ex_Risk = abs(&ex_risk_target-Extra_Risk);
				    call symput('Delta_Ex_Risk',Diff_Ex_Risk);
 
                                     output;
 
              * END; * corresponds to X_Levels;
	      STOP;
 
	      run;
 
 %Mend BEIR4;
 
 
 
 /* --------------------------------------------------------------------
                   BT: March 2019: parameters for the convergence that are used
		   in the modified version of the BEIR4 macro.
  ----------------------------------------------------------*/
 %macro Converge_BEIR4 (init_exposure_conc=, ex_risk_target=, conv_criterion=, max_iteration=);
 
         %Let Delta_Ex_Risk = 1; * initial high value to make sure loop is run at least once
						      (i.e., macro BEIR4 is called at least once);
						      
	 /* BT 4/15/19: added next line to avoid error during compiling of BEIR4*/
         %Let Extra_Riskm = 1;
 
	 %Let i=1; * first time through loop;
 
         %Do %Until (%sysevalf(&Delta_Ex_risk < &conv_criterion) OR %sysevalf(&i >
    &max_iteration));
 
			    * first time through loop, set expsosure_conc=init_exposure_conc;
	        %If &i=1 %Then
		           %Do;
			            %Let exposure_conc=&init_exposure_conc;
 
			   %End;
	       %If &i>1 %Then
			 %Do;
			 data tempBEIRCONVERGE;
			            *BEIR4 has run at least once. Adjust exposure_conc
				            Extra_Riskm is created in BEIR4 (=Extra_Risk);
				    NumLoops=&i;
				    thisExposureConc=&exposure_conc;

        /* BT 4/15/19: replaced all of the convergence code with the same code that we used
					      in the meso code.*/
				      numvar=&ex_risk_target;
				      denvar=&Extra_Riskm;
				      thisexposureconc = thisexposureconc * (numvar/denvar);
 
 *update the concentration;
  				      call symput('exposure_conc',thisexposureconc);
				      output;
 			       Run;
 
			%End; *Corresponds to If i>1 statement;
		%BEIR4;
		%Let i=%eval(&i+1);
	%End;
	%Let EC_1Percent = &exposure_conc;
 
 /*---------------------------------------------------------------+
 | Report results if convergence criterion met:	|
 
 +---------------------------------------------------------------*/
 %If %sysevalf(&Delta_Ex_risk < &conv_criterion) %then %do;
 title5 "based on beta=&COEF, Concentration=&EC_1Percent, and LastAge=&LastAge";
 
 data _null_;	/* Modified 26-july-00 */
  pointer=1;
  set allcause (keep=age
      rename=(age=ageall0)) point=pointer nobs=n_all;
  set cause (keep=age
      rename=(age=ageCs0)) point=pointer nobs=n_cause;
  pointer=n_all;
  set allcause (keep=age
      rename=(age=ageall1)) point=pointer nobs=n_all;
  pointer=n_cause;
  set cause (keep=age
      rename=(age=ageCs1)) point=pointer nobs=n_cause;
  Tmp = sum(min(AgeAll1,AgeCs1,(&Lastage-1)),1);
  file PRINT;
  if ageall0 NE ageCs0 then DO;
   put /"ERROR: The initial age for all-causes rate differs from the"
    /" initial age for the cause-specific rate.";
   END;
   else DO;
    put / "Values of macro variables used in this computation: "
    // @3 "Value" @17 "Macro_Var" @29 "Description"
     / @3 "-----" @17 "---------" @29 "----------------------------"
    // @3 "&Model " @17 "MODEL" @29 "1 = Loglinear Relative Rate,"
     /	          @29 "2 = Linear Relative Rate, "
     /		  @29 "3 = Linear Absolute Rate, "
     /		  @29 "4 = 'Power' Relative Rate, "
     /		  @29 "0 = User defined.	"
     / @3 "&Coef " @17 "COEF" @29 "Exposure parameter estimate"
    // @3 "&Lag " @17 "LAG" @29 "Exposure Lag "
    // @3 "&Age1st_x" @17 "AGE1ST_X" @29 "Age exposure begins"
     / @3 "&Duration" @17 "DURATION" @29 "Duration of exposure"
     / @3 "&EnvAdj" @17 "ENVADJ" @29 "Adjust dose from intermittent"
     /	         @29 "occupational exposures to "
     /	         @29 "continuous environmental exposures"
                   / @3 "-----" @17 "---------" @29 "----------------------------"
     // "--------------------------------------------------------------"
                   // @3 "EC1% = " @10 "&EC_1Percent" @25 "(μg Cr(VI)/m3); Rx = " @39 "&Extra_Riskm"
                   // "---------------------------------------------------------------"
     /"The risks are calculated from age " ageall0 " up to age " Tmp "."
    // ;

   if ageall1 NE ageCs1 then
    put /"WARNING: The last age for the all-causes rates differs from"
     /"	  the last age for the cause-specific rates, suggesting"
     /"	  the possibility that the rates weren't entered as desired."
     /;
   END;
  Stop;
  run;
 /* BT 7/5/19: Start of code that was added to merge variables for unexposed risk
                               (S_1i and S_1ix) to the rest of the output, by age;
 Data newSRCData(keep=SRC_age SRC_S_1i SRC_S_1ix);
                set ex_Risk;
                SRC_age=0; SRC_S_1i=1; SRC_S_1ix=1;
		output;
 
                do obsnum=1 to last-1;
		set ex_Risk point=obsnum nobs=last;
		if _error_ then abort;
		        SRC_age=age+1; SRC_S_1i=S_1i; SRC_S_1ix=S_1ix;
		output;
		end;

		
    stop;
   run;
 * rename variables to enable overwriting the values of S_1i and S_lix in ex_risk with the values
 in newSRCData;
 
 * Data file tempSRCData has age=0-85 while the ex_Risk file has age 0-84, with last two records
                both having age=84.;
 Data tempSRCData; Set newSRCData(rename=(SRC_Age=age SRC_S_1i=S_1i SRC_S_1ix=S_1ix));
         if age=&LastAge then age=%sysevalf(&Lastage-1); Else age=age;
 Run;
 
 * there are duplicate values for age in both ex_risk and tempSRCData
	        which may produce too many records. if that happens, then we use two set
 statements;
 Data ex_risk; merge ex_risk tempSRCData; By Age; Run;
 
 /* BT 7/5/19: End of code that was added to merge variables for unexposed risk
		               (S_1i and S_1ix) to the rest of the output, by age;
 */
 
 *BT 7/3/19: made the these changes to the following Proc Print procedure:
               - commented out the label option and added the split, uniform and width= options
               - included all variables to the format statement;
 proc print data=ex_risk /*label*/ noobs split='/' width=FULL;
  format age F4. Xdose E11. hi E11. hstari E11. hix E11. hstarix E11. qi E11. qix E11.
                              S_1i E11. S_1ix E11. R0 E11. Risk E11. Ex_Risk E11. ;
	     label	Age	= "Age at start of year (i)"
	                      XDose = "CE5(adj) (μg Cr(VI)/m3-yrs)"
 
  R0   = "Cumulative Risk of lung cancer (unexposed) (R0)"
  Risk  = "Cumulative risk of lung cancer (exposed) (Re)"
  Ex_Risk     = "Excess risk/[Rx-Ro]/ /(Ex_Risk)"
  hi  = "Lung Cancer hazard (unexposed) (hi)"
  hix        = "Lung Cancer hazard (exposed) (hei)"
  hstari     = "All cause hazard (unexposed) (h*i)"
  hstarix    = "All cause hazard (exposed) (he*i)"
  qi = "Probability of surviving year i assuming alive at start (unexposed) (qi)"
  qix = "Probability of surviving year i assuming alive at start (exposed) (qei)"
  S_1i	      = "Probability of surviving to end of year i (unexposed) (S1,i)"
  S_1ix	      = "Probability of surviving to end of yeari (exposed) (Se1,i)";
 
                   Var Age Xdose hi hstari hix hstarix qi qix S_1i S_1ix R0 Risk Extra_risk; *BT
7/3/19: Var statement added;
               label Extra_risk="Extra Risk (Re ¢€“ R0)\(1 ¢€“ R0)";
 run;
 %End; *end of the If statement that tests if convergence was met;
 %Mend Converge_BEIR4;
 
 /* -----------------------------------------------------------------------+
 | March 2019: BT (SRC) Added maxro CONVERGE_BEIR4 which iteratively |
 | runs macro BEIR4 until the EXPOSURE_CONCENTRATION corresponds to an |
 | extra_risk=0.01 (the point of departure [POD]).	|
 |
 | In addition to the parameter for CONVERGE_BEIR4, the user should also|
 | review parameters and data that are assigned/entered in Part 1 and |
 | Part II (see above). Parameters for CONVERGE_BEIR4 are defined below |
 +----------------------------------------------------------------------*/

         *%BEIR4; * originally called macr BEIR4 directly. Now BEIR4 is called by Converge_BEIR4;
	 
        %Converge_BEIR4(init_exposure_conc=1, /* initial exposure concentration (initial guess) */
	       ex_risk_target=0.01000000, /*the point of departure (POD)-the target extra risk */
	       conv_criterion=0.00000001,
	       max_iteration=200); /* to avoid excessively long run times */
 
 Run;

	
	Values of macro variables used in this computation:
	Value Macro_Var Description
	----- --------- ----------------------------
	1 MODEL 1 = Loglinear Relative Rate,
	2 = Linear Relative Rate,
	3 = Linear Absolute Rate,
	4 = 'Power' Relative Rate,
	0 = User defined.
	0.001298 COEF Exposure parameter estimate
	5 LAG Exposure Lag
	16 AGE1ST_X Age exposure begins
	85 DURATION Duration of exposure
	Yes ENVADJ Adjust dose from intermittent
	occupational exposures to
	continuous environmental exposures
	----- --------- ----------------------------
	---------------------------------------------------------------
	EC1% = 1.1795769661 (f/ml); Rx = 0.0099999947
	---------------------------------------------------------------
	The risks are calculated from age 0 up to age 85 .

Age at start of year (i) | CE10(adj) (f\cc-yr) | Lung Cancer hazard (unexposed) (hi) | All cause hazard (unexposed) (h*i) | Lung Cancer hazard (exposed) (hei) | All cause hazard (exposed) (he*i) | Probability of surviving year i assuming alive at start (unexposed) (qi) | Probability of surviving year i assuming alive at start (exposed) (qei) | Probability of surviving to end of year i (unexposed) (S1,i) | Probability of surviving to end of yeari (exposed) (Se1,i) | Cumulative Risk of lung cancer (unexposed) (R0) | Cumulative risk of lung cancer (exposed) (Re) | Extra Risk (Re-R0)\(1-R0)
0 | 0.0000E+00 | 0.0000E+00 | 5.7968E−03 | 0.0000E+00 | 5.7968E−03 | 9.9422E−01 | 9.9422E−01 | 1.0000E+00 | 1.0000E+00 | 0.0000E+00 | 0.0000E+00 | .
1 | 0.0000E+00 | 3.8000E−07 | 3.8228E−04 | 3.8000E−07 | 3.8228E−04 | 9.9962E−01 | 9.9962E−01 | 9.9422E−01 | 9.9422E−01 | 3.7773E−07 | 3.7773E−07 | .
2 | 0.0000E+00 | 3.8000E−07 | 2.4152E−04 | 3.8000E−07 | 2.4152E−04 | 9.9976E−01 | 9.9976E−01 | 9.9384E−01 | 9.9384E−01 | 7.5534E−07 | 7.5534E−07 | .
3 | 0.0000E+00 | 3.8000E−07 | 1.9124E−04 | 3.8000E−07 | 1.9124E−04 | 9.9981E−01 | 9.9981E−01 | 9.9360E−01 | 9.9360E−01 | 1.1329E−06 | 1.1329E−06 | .
4 | 0.0000E+00 | 3.8000E−07 | 1.5101E−04 | 3.8000E−07 | 1.5101E−04 | 9.9985E−01 | 9.9985E−01 | 9.9341E−01 | 9.9341E−01 | 1.5103E−06 | 1.5103E−06 | .
5 | 0.0000E+00 | 1.0000E−07 | 1.4096E−04 | 1.0000E−07 | 1.4096E−04 | 9.9986E−01 | 9.9986E−01 | 9.9326E−01 | 9.9326E−01 | 1.6097E−06 | 1.6097E−06 | .
6 | 0.0000E+00 | 1.0000E−07 | 1.3091E−04 | 1.0000E−07 | 1.3091E−04 | 9.9987E−01 | 9.9987E−01 | 9.9312E−01 | 9.9312E−01 | 1.7090E−06 | 1.7090E−06 | .
7 | 0.0000E+00 | 1.0000E−07 | 1.1078E−04 | 1.0000E−07 | 1.1078E−04 | 9.9989E−01 | 9.9989E−01 | 9.9299E−01 | 9.9299E−01 | 1.8083E−06 | 1.8083E−06 | .
8 | 0.0000E+00 | 1.0000E−07 | 1.0072E−04 | 1.0000E−07 | 1.0072E−04 | 9.9990E−01 | 9.9990E−01 | 9.9288E−01 | 9.9288E−01 | 1.9075E−06 | 1.9075E−06 | .
9 | 0.0000E+00 | 1.0000E−07 | 1.0073E−04 | 1.0000E−07 | 1.0073E−04 | 9.9990E−01 | 9.9990E−01 | 9.9278E−01 | 9.9278E−01 | 2.0068E−06 | 2.0068E−06 | .
10 | 0.0000E+00 | 1.9000E−07 | 9.0668E−05 | 1.9000E−07 | 9.0668E−05 | 9.9991E−01 | 9.9991E−01 | 9.9268E−01 | 9.9268E−01 | 2.1954E−06 | 2.1954E−06 | .
11 | 0.0000E+00 | 1.9000E−07 | 1.0075E−04 | 1.9000E−07 | 1.0075E−04 | 9.9990E−01 | 9.9990E−01 | 9.9259E−01 | 9.9259E−01 | 2.3840E−06 | 2.3840E−06 | .
12 | 0.0000E+00 | 1.9000E−07 | 1.3099E−04 | 1.9000E−07 | 1.3099E−04 | 9.9987E−01 | 9.9987E−01 | 9.9249E−01 | 9.9249E−01 | 2.5726E−06 | 2.5726E−06 | .
13 | 0.0000E+00 | 1.9000E−07 | 1.9148E−04 | 1.9000E−07 | 1.9148E−04 | 9.9981E−01 | 9.9981E−01 | 9.9236E−01 | 9.9236E−01 | 2.7611E−06 | 2.7611E−06 | .
14 | 0.0000E+00 | 1.9000E−07 | 2.6209E−04 | 1.9000E−07 | 2.6209E−04 | 9.9974E−01 | 9.9974E−01 | 9.9217E−01 | 9.9217E−01 | 2.9496E−06 | 2.9496E−06 | .
15 | 0.0000E+00 | 3.3000E−07 | 3.3275E−04 | 3.3000E−07 | 3.3275E−04 | 9.9967E−01 | 9.9967E−01 | 9.9191E−01 | 9.9191E−01 | 3.2769E−06 | 3.2769E−06 | .
16 | 0.0000E+00 | 3.3000E−07 | 4.2366E−04 | 3.3000E−07 | 4.2366E−04 | 9.9958E−01 | 9.9958E−01 | 9.9158E−01 | 9.9158E−01 | 3.6040E−06 | 3.6040E−06 | .
17 | 0.0000E+00 | 3.3000E−07 | 5.0459E−04 | 3.3000E−07 | 5.0459E−04 | 9.9950E−01 | 9.9950E−01 | 9.9116E−01 | 9.9116E−01 | 3.9310E−06 | 3.9310E−06 | .
18 | 0.0000E+00 | 3.3000E−07 | 6.0584E−04 | 3.3000E−07 | 6.0584E−04 | 9.9939E−01 | 9.9939E−01 | 9.9066E−01 | 9.9066E−01 | 4.2578E−06 | 4.2578E−06 | .
19 | 0.0000E+00 | 3.3000E−07 | 6.9717E−04 | 3.3000E−07 | 6.9717E−04 | 9.9930E−01 | 9.9930E−01 | 9.9006E−01 | 9.9006E−01 | 4.5844E−06 | 4.5844E−06 | .
20 | 0.0000E+00 | 4.5000E−07 | 7.9881E−04 | 4.5000E−07 | 7.9881E−04 | 9.9920E−01 | 9.9920E−01 | 9.8937E−01 | 9.8937E−01 | 5.0295E−06 | 5.0295E−06 | .
21 | 1.7939E+00 | 4.5000E−07 | 8.9056E−04 | 4.5105E−07 | 8.9056E−04 | 9.9911E−01 | 9.9911E−01 | 9.8858E−01 | 9.8858E−01 | 5.4741E−06 | 5.4752E−06 | .
22 | 5.3818E+00 | 4.5000E−07 | 9.7243E−04 | 4.5315E−07 | 9.7243E−04 | 9.9903E−01 | 9.9903E−01 | 9.8770E−01 | 9.8770E−01 | 5.9184E−06 | 5.9225E−06 | .
23 | 8.9697E+00 | 4.5000E−07 | 1.0241E−03 | 4.5527E−07 | 1.0241E−03 | 9.9898E−01 | 9.9898E−01 | 9.8674E−01 | 9.8674E−01 | 6.3622E−06 | 6.3715E−06 | .
24 | 1.2558E+01 | 4.5000E−07 | 1.0861E−03 | 4.5739E−07 | 1.0861E−03 | 9.9891E−01 | 9.9891E−01 | 9.8573E−01 | 9.8573E−01 | 6.8055E−06 | 6.8222E−06 | .
25 | 1.6145E+01 | 1.2000E−06 | 1.1279E−03 | 1.2254E−06 | 1.1280E−03 | 9.9887E−01 | 9.9887E−01 | 9.8466E−01 | 9.8466E−01 | 7.9865E−06 | 8.0281E−06 | .
26 | 1.9733E+01 | 1.2000E−06 | 1.1597E−03 | 1.2311E−06 | 1.1598E−03 | 9.9884E−01 | 9.9884E−01 | 9.8355E−01 | 9.8355E−01 | 9.1660E−06 | 9.2383E−06 | .
27 | 2.3321E+01 | 1.2000E−06 | 1.2120E−03 | 1.2369E−06 | 1.2121E−03 | 9.9879E−01 | 9.9879E−01 | 9.8241E−01 | 9.8241E−01 | 1.0344E−05 | 1.0453E−05 | .
28 | 2.6909E+01 | 1.2000E−06 | 1.2543E−03 | 1.2427E−06 | 1.2544E−03 | 9.9875E−01 | 9.9875E−01 | 9.8122E−01 | 9.8122E−01 | 1.1521E−05 | 1.1671E−05 | .
29 | 3.0497E+01 | 1.2000E−06 | 1.2968E−03 | 1.2485E−06 | 1.2968E−03 | 9.9870E−01 | 9.9870E−01 | 9.7999E−01 | 9.7999E−01 | 1.2696E−05 | 1.2894E−05 | .
30 | 3.4085E+01 | 3.8200E−06 | 1.3496E−03 | 3.9928E−06 | 1.3498E−03 | 9.9865E−01 | 9.9865E−01 | 9.7872E−01 | 9.7872E−01 | 1.6432E−05 | 1.6799E−05 | .
31 | 3.7673E+01 | 3.8200E−06 | 1.4027E−03 | 4.0114E−06 | 1.4029E−03 | 9.9860E−01 | 9.9860E−01 | 9.7740E−01 | 9.7740E−01 | 2.0163E−05 | 2.0717E−05 | .
32 | 4.1261E+01 | 3.8200E−06 | 1.4559E−03 | 4.0302E−06 | 1.4561E−03 | 9.9855E−01 | 9.9854E−01 | 9.7603E−01 | 9.7603E−01 | 2.3889E−05 | 2.4648E−05 | .
33 | 4.4848E+01 | 3.8200E−06 | 1.5094E−03 | 4.0490E−06 | 1.5097E−03 | 9.9849E−01 | 9.9849E−01 | 9.7461E−01 | 9.7461E−01 | 2.7609E−05 | 2.8591E−05 | .
34 | 4.8436E+01 | 3.8200E−06 | 1.5529E−03 | 4.0679E−06 | 1.5531E−03 | 9.9845E−01 | 9.9845E−01 | 9.7314E−01 | 9.7314E−01 | 3.1324E−05 | 3.2547E−05 | .
35 | 5.2024E+01 | 1.0740E−05 | 1.6171E−03 | 1.1490E−05 | 1.6179E−03 | 9.9838E−01 | 9.9838E−01 | 9.7163E−01 | 9.7163E−01 | 4.1751E−05 | 4.3702E−05 | .
36 | 5.5612E+01 | 1.0740E−05 | 1.6817E−03 | 1.1544E−05 | 1.6825E−03 | 9.9832E−01 | 9.9832E−01 | 9.7006E−01 | 9.7006E−01 | 5.2160E−05 | 5.4891E−05 | .
37 | 5.9200E+01 | 1.0740E−05 | 1.7466E−03 | 1.1598E−05 | 1.7475E−03 | 9.9825E−01 | 9.9825E−01 | 9.6843E−01 | 9.6843E−01 | 6.2552E−05 | 6.6113E−05 | .
38 | 6.2788E+01 | 1.0740E−05 | 1.7911E−03 | 1.1652E−05 | 1.7920E−03 | 9.9821E−01 | 9.9821E−01 | 9.6674E−01 | 9.6674E−01 | 7.2926E−05 | 7.7367E−05 | .
39 | 6.6376E+01 | 1.0740E−05 | 1.8670E−03 | 1.1706E−05 | 1.8680E−03 | 9.9813E−01 | 9.9813E−01 | 9.6501E−01 | 9.6501E−01 | 8.3280E−05 | 8.8653E−05 | .
40 | 6.9964E+01 | 3.1310E−05 | 1.9329E−03 | 3.4286E−05 | 1.9359E−03 | 9.9807E−01 | 9.9807E−01 | 9.6321E−01 | 9.6320E−01 | 1.1341E−04 | 1.2165E−04 | .
41 | 7.3552E+01 | 3.1310E−05 | 2.0409E−03 | 3.4447E−05 | 2.0440E−03 | 9.9796E−01 | 9.9796E−01 | 9.6135E−01 | 9.6134E−01 | 1.4348E−04 | 1.5473E−04 | .
42 | 7.7139E+01 | 3.1310E−05 | 2.1600E−03 | 3.4607E−05 | 2.1632E−03 | 9.9784E−01 | 9.9784E−01 | 9.5939E−01 | 9.5938E−01 | 1.7348E−04 | 1.8789E−04 | .
43 | 8.0727E+01 | 3.1310E−05 | 2.3112E−03 | 3.4769E−05 | 2.3147E−03 | 9.9769E−01 | 9.9769E−01 | 9.5732E−01 | 9.5731E−01 | 2.0342E−04 | 2.2114E−04 | .
44 | 8.4315E+01 | 3.1310E−05 | 2.4740E−03 | 3.4931E−05 | 2.4776E−03 | 9.9753E−01 | 9.9753E−01 | 9.5511E−01 | 9.5509E−01 | 2.3329E−04 | 2.5446E−04 | .
45 | 8.7903E+01 | 8.5060E−05 | 2.6485E−03 | 9.5341E−05 | 2.6588E−03 | 9.9736E−01 | 9.9734E−01 | 9.5275E−01 | 9.5273E−01 | 3.1422E−04 | 3.4517E−04 | .
46 | 9.1491E+01 | 8.5060E−05 | 2.8455E−03 | 9.5786E−05 | 2.8562E−03 | 9.9716E−01 | 9.9715E−01 | 9.5023E−01 | 9.5020E−01 | 3.9494E−04 | 4.3606E−04 | .
47 | 9.5079E+01 | 8.5060E−05 | 3.0865E−03 | 9.6233E−05 | 3.0976E−03 | 9.9692E−01 | 9.9691E−01 | 9.4753E−01 | 9.4749E−01 | 4.7541E−04 | 5.2710E−04 | .
48 | 9.8667E+01 | 8.5060E−05 | 3.3615E−03 | 9.6682E−05 | 3.3731E−03 | 9.9664E−01 | 9.9663E−01 | 9.4461E−01 | 9.4456E−01 | 5.5562E−04 | 6.1826E−04 | .
49 | 1.0225E+02 | 8.5060E−05 | 3.6927E−03 | 9.7133E−05 | 3.7047E−03 | 9.9631E−01 | 9.9630E−01 | 9.4144E−01 | 9.4138E−01 | 6.3555E−04 | 7.0953E−04 | .
50 | 1.0584E+02 | 2.4321E−04 | 4.0381E−03 | 2.7903E−04 | 4.0739E−03 | 9.9597E−01 | 9.9593E−01 | 9.3797E−01 | 9.3790E−01 | 8.6322E−04 | 9.7070E−04 | .
51 | 1.0943E+02 | 2.4321E−04 | 4.4092E−03 | 2.8033E−04 | 4.4464E−03 | 9.9560E−01 | 9.9556E−01 | 9.3419E−01 | 9.3408E−01 | 1.0899E−03 | 1.2320E−03 | .
52 | 1.1302E+02 | 2.4321E−04 | 4.8284E−03 | 2.8164E−04 | 4.8669E−03 | 9.9518E−01 | 9.9514E−01 | 9.3008E−01 | 9.2994E−01 | 1.3156E−03 | 1.4932E−03 | .
53 | 1.1661E+02 | 2.4321E−04 | 5.3079E−03 | 2.8295E−04 | 5.3477E−03 | 9.9471E−01 | 9.9467E−01 | 9.2560E−01 | 9.2542E−01 | 1.5401E−03 | 1.7544E−03 | .
54 | 1.2019E+02 | 2.4321E−04 | 5.7950E−03 | 2.8427E−04 | 5.8360E−03 | 9.9422E−01 | 9.9418E−01 | 9.2070E−01 | 9.2049E−01 | 1.7634E−03 | 2.0153E−03 | .
55 | 1.2378E+02 | 5.4508E−04 | 6.3014E−03 | 6.4009E−04 | 6.3964E−03 | 9.9372E−01 | 9.9362E−01 | 9.1538E−01 | 9.1513E−01 | 2.2608E−03 | 2.5992E−03 | .
56 | 1.2737E+02 | 5.4508E−04 | 6.8172E−03 | 6.4307E−04 | 6.9151E−03 | 9.9321E−01 | 9.9311E−01 | 9.0963E−01 | 9.0930E−01 | 2.7549E−03 | 3.1819E−03 | .
57 | 1.3096E+02 | 5.4508E−04 | 7.3433E−03 | 6.4607E−04 | 7.4443E−03 | 9.9268E−01 | 9.9258E−01 | 9.0345E−01 | 9.0303E−01 | 3.2455E−03 | 3.7632E−03 | .
58 | 1.3455E+02 | 5.4508E−04 | 7.9032E−03 | 6.4909E−04 | 8.0072E−03 | 9.9213E−01 | 9.9202E−01 | 8.9684E−01 | 8.9633E−01 | 3.7325E−03 | 4.3427E−03 | .
59 | 1.3813E+02 | 5.4508E−04 | 8.4874E−03 | 6.5212E−04 | 8.5945E−03 | 9.9155E−01 | 9.9144E−01 | 8.8978E−01 | 8.8919E−01 | 4.2154E−03 | 4.9200E−03 | .
60 | 1.4172E+02 | 8.7599E−04 | 9.1319E−03 | 1.0529E−03 | 9.3088E−03 | 9.9091E−01 | 9.9073E−01 | 8.8226E−01 | 8.8158E−01 | 4.9848E−03 | 5.8439E−03 | .
61 | 1.4531E+02 | 8.7599E−04 | 9.8165E−03 | 1.0578E−03 | 9.9983E−03 | 9.9023E−01 | 9.9005E−01 | 8.7424E−01 | 8.7341E−01 | 5.7468E−03 | 6.7633E−03 | .
62 | 1.4890E+02 | 8.7599E−04 | 1.0521E−02 | 1.0628E−03 | 1.0707E−02 | 9.8953E−01 | 9.8935E−01 | 8.6570E−01 | 8.6472E−01 | 6.5012E−03 | 7.6773E−03 | .
63 | 1.5248E+02 | 8.7599E−04 | 1.1246E−02 | 1.0677E−03 | 1.1438E−02 | 9.8882E−01 | 9.8863E−01 | 8.5664E−01 | 8.5551E−01 | 7.2474E−03 | 8.5856E−03 | .
64 | 1.5607E+02 | 8.7599E−04 | 1.1995E−02 | 1.0727E−03 | 1.2192E−02 | 9.8808E−01 | 9.8788E−01 | 8.4706E−01 | 8.4578E−01 | 7.9850E−03 | 9.4873E−03 | .
65 | 1.5966E+02 | 1.3188E−03 | 1.2794E−02 | 1.6224E−03 | 1.3098E−02 | 9.8729E−01 | 9.8699E−01 | 8.3696E−01 | 8.3553E−01 | 9.0817E−03 | 1.0834E−02 | .
66 | 1.6325E+02 | 1.3188E−03 | 1.3708E−02 | 1.6300E−03 | 1.4019E−02 | 9.8639E−01 | 9.8608E−01 | 8.2632E−01 | 8.2466E−01 | 1.0164E−02 | 1.2169E−02 | .
67 | 1.6684E+02 | 1.3188E−03 | 1.4733E−02 | 1.6376E−03 | 1.5051E−02 | 9.8538E−01 | 9.8506E−01 | 8.1507E−01 | 8.1318E−01 | 1.1231E−02 | 1.3491E−02 | .
68 | 1.7042E+02 | 1.3188E−03 | 1.5901E−02 | 1.6453E−03 | 1.6228E−02 | 9.8422E−01 | 9.8390E−01 | 8.0315E−01 | 8.0103E−01 | 1.2282E−02 | 1.4798E−02 | .
69 | 1.7401E+02 | 1.3188E−03 | 1.7239E−02 | 1.6529E−03 | 1.7573E−02 | 9.8291E−01 | 9.8258E−01 | 7.9048E−01 | 7.8814E−01 | 1.3315E−02 | 1.6089E−02 | .
70 | 1.7760E+02 | 1.9811E−03 | 1.8603E−02 | 2.4947E−03 | 1.9116E−02 | 9.8157E−01 | 9.8107E−01 | 7.7697E−01 | 7.7441E−01 | 1.4840E−02 | 1.8003E−02 | .
71 | 1.8119E+02 | 1.9811E−03 | 2.0533E−02 | 2.5063E−03 | 2.1059E−02 | 9.7968E−01 | 9.7916E−01 | 7.6265E−01 | 7.5974E−01 | 1.6336E−02 | 1.9887E−02 | .
72 | 1.8478E+02 | 1.9811E−03 | 2.2345E−02 | 2.5180E−03 | 2.2882E−02 | 9.7790E−01 | 9.7738E−01 | 7.4715E−01 | 7.4391E−01 | 1.7799E−02 | 2.1739E−02 | .
73 | 1.8836E+02 | 1.9811E−03 | 2.4496E−02 | 2.5298E−03 | 2.5044E−02 | 9.7580E−01 | 9.7527E−01 | 7.3064E−01 | 7.2708E−01 | 1.9229E−02 | 2.3556E−02 | .
74 | 1.9195E+02 | 1.9811E−03 | 2.6694E−02 | 2.5416E−03 | 2.7255E−02 | 9.7366E−01 | 9.7311E−01 | 7.1296E−01 | 7.0910E−01 | 2.0623E−02 | 2.5333E−02 | .
75 | 1.9554E+02 | 2.6576E−03 | 2.9472E−02 | 3.4255E−03 | 3.0239E−02 | 9.7096E−01 | 9.7021E−01 | 6.9418E−01 | 6.9004E−01 | 2.2441E−02 | 2.7662E−02 | .
76 | 1.9913E+02 | 2.6576E−03 | 3.2525E−02 | 3.4415E−03 | 3.3309E−02 | 9.6800E−01 | 9.6724E−01 | 6.7402E−01 | 6.6948E−01 | 2.4204E−02 | 2.9928E−02 | .
77 | 2.0272E+02 | 2.6576E−03 | 3.6079E−02 | 3.4575E−03 | 3.6879E−02 | 9.6456E−01 | 9.6379E−01 | 6.5245E−01 | 6.4755E−01 | 2.5907E−02 | 3.2126E−02 | .
78 | 2.0630E+02 | 2.6576E−03 | 4.0056E−02 | 3.4737E−03 | 4.0872E−02 | 9.6074E−01 | 9.5995E−01 | 6.2933E−01 | 6.2410E−01 | 2.7546E−02 | 3.4250E−02 | .
79 | 2.0989E+02 | 2.6576E−03 | 4.4352E−02 | 3.4899E−03 | 4.5184E−02 | 9.5662E−01 | 9.5582E−01 | 6.0462E−01 | 5.9911E−01 | 2.9118E−02 | 3.6294E−02 | .
80 | 2.1348E+02 | 3.0963E−03 | 4.9367E−02 | 4.0849E−03 | 5.0356E−02 | 9.5183E−01 | 9.5089E−01 | 5.7839E−01 | 5.7264E−01 | 3.0865E−02 | 3.8576E−02 | .
81 | 2.1707E+02 | 3.0963E−03 | 5.4690E−02 | 4.1039E−03 | 5.5698E−02 | 9.4678E−01 | 9.4582E−01 | 5.5053E−01 | 5.4452E−01 | 3.2524E−02 | 4.0749E−02 | .
82 | 2.2065E+02 | 3.0963E−03 | 6.1072E−02 | 4.1231E−03 | 6.2099E−02 | 9.4076E−01 | 9.3979E−01 | 5.2123E−01 | 5.1502E−01 | 3.4090E−02 | 4.2808E−02 | .
83 | 2.2424E+02 | 3.0963E−03 | 6.8884E−02 | 4.1423E−03 | 6.9930E−02 | 9.3344E−01 | 9.3246E−01 | 4.9035E−01 | 4.8401E−01 | 3.5557E−02 | 4.4745E−02 | .
84 | 2.2783E+02 | 3.0963E−03 | 7.6927E−02 | 4.1617E−03 | 7.7992E−02 | 9.2596E−01 | 9.2497E−01 | 4.5771E−01 | 4.5132E−01 | 3.6921E−02 | 4.6552E−02 | .
84 | 2.2783E+02 | 3.0963E−03 | 7.6927E−02 | 4.1617E−03 | 7.7992E−02 | 9.2596E−01 | 9.2497E−01 | 4.2382E−01 | 4.1746E−01 | 3.6921E−02 | 4.6552E−02 | 0.0099999947