# APPENDIX D DOSE-RESPONSE MODELING

This appendix provides technical detail on dose-response evaluation and determination of points of departure (PODs) for relevant toxicological endpoints. Figure D-1 provides an overview of the process of RfD/RfC derivation. The endpoints were modeled using EPA’s Benchmark Dose Software (BMDS, Version 3.2). Sections D.1 (noncancer) and D.2 (cancer) describe the common practices used in evaluating the model fit and selecting the appropriate model for determining the POD, as outlined in the Benchmark Dose Technical Guidance Document (U.S. EPA, 2012a). Logfiles of BMD model outputs are contained in (U.S. EPA, 2021a). Logfiles of selected BMD model outputs (such as those used for the overall RfD and OSF) are presented in Appendix D.8.

Some statistical models (Gamma, dichotomous Hill, Weibull, and log-logistic) were run with constrained slope or power parameters (≥1) (U.S. EPA, 2012a). As noted in the Benchmark Dose Software (BMDS) version 3.2 user guide (U.S. EPA, 2020a), some models with unrestricted coefficients can give complicated shapes, in particular for high-degree polynomial models (which produce unrealistic “wavy” results with negative response rates). Although Dichotomous model averaging is an available feature of BMDS 3.2, only frequentist models were routinely run in this assessment.

Figure D-1 Overview of the process for deriving candidate, organ-specific, and overall RfDs (process also applicable to RfCs).

## D.1 BENCHMARK DOSE MODELING SUMMARY FOR NONCANCER ENDPOINTS

For this assessment, dose-response modeling of endpoints for the oral route of exposure was performed based on the time-weighted average daily dose of Cr(VI), in mg/kg-day. This value could then be converted to an internal rodent dose, depending on the tissue or endpoint. The time-weighted average was calculated based on time-course dose data available through the data collection time for each endpoint. For example, for endpoints measured at 12 months in the NTP (2008) study, the time-weighted average daily dose over 12 months was applied, as opposed to the average daily dose over the full 2-year bioassay.

For dose-response modeling of endpoints for the inhalation route, inhaled concentration was used. Adjustments for respiratory-tract particle dosimetry and 24-hour/day, time conversion were performed during the interspecies extrapolation step.

The noncancer endpoints selected for dose-response modeling are presented in Tables D-1 through D-3 (oral) and Table D-4 (inhalation). For each endpoint, the exposure doses and data used for the modeling are presented.

Table D-1 Noncancer endpoints selected for dose-response modeling for Cr(VI) (oral) from NTP (2008)

Species/sex endpoint | Doses and effect data
Mouse/male | Cr(VI) mg/L | 0 | 5 | 10 | 30 | 90
| TWA dose mg/kg-d | 0 | 0.450 | 0.914 | 2.40 | 5.70
Diffuse epithelial hyperplasia (duodenum) at lifetime | Incidence /Total | 0/39 | 11/43 | 18/45 | 42/48 | 32/40
Mouse/female | Cr(VI) mg/L | 0 | 5 | 20 | 60 | 180
| TWA dose mg/kg-d | 0 | 0.302 | 1.18 | 3.24 | 8.89
Diffuse epithelial hyperplasia (duodenum) at lifetime | Incidence /Total | 0/42 | 16/42 | 35/48 | 31/42 | 42/48
Chronic inflammation (liver) at lifetime | Incidence/Total | 16/49 | 21/50 | 22/50 | 27/50 | 24/50
Rat/female | Cr(VI) mg/L | 0 | 5 | 20 | 60 | 180
Rat/female | TWA dose mg/kg-d | 0 | 0.248 | 0.961 | 2.60 | 7.13
Fatty change (liver) at lifetime | Incidence /Total | 3/50 | 7/50 | 10/50 | 13/50 | 16/50
Chronic inflammation (liver) at lifetime | Incidence /Total | 12/50 | 21/50 | 28/50 | 35/50 | 39/50
Rat/male | Cr(VI) mg/L | 0 | 5 | 20 | 60 | 180
| TWA dose mg/kg-d (lifetime) | 0 | 0.200 | 0.796 | 2.10 | 6.07
| TWA dose mg/kg-d (12 mo) | 0 | 0.237 | 0.938 | 2.49 | 7.19
| TWA dose mg/kg-d (3 mo) | 0 | 0.401 | 1.58 | 4.16 | 11.7
Chronic Inflammation (liver) at lifetime | Incidence/Total | 19/50 | 25/50 | 21/49 | 28/50^a^ | 26/49
ALT (liver) at 12 mo. | IU/L ± SE, n = 10/group | 102 ± 6 | 107 ± 8 | 135 ± 10 | 261 ± 23 | 223 ± 15
ALT (liver) at 3 mo. | IU/L ± SE, n = 10/group | 82 ± 4 | 82 ± 12 | 135 ± 18 | 176 ± 13 | 216 ± 21
Rat/male | N | 10 | 10 | 10 | 8 | 10
| TWA dose mg/kg-d (12 mo) | 0 | 0.237 | 0.938 | 2.49 | 7.19
| RBC (10^6^/μL, mean ± SE) | 9.27 ± 0.10 | 9.17 ± 0.07 | 9.4 ± 0.12 | 9.61 ± 0.11 | 9.74 ± 0.08
| MCV (fL, mean ± SE) | 52.6 ± 0.2 | 52.4 ± 0.2 | 51.9 ± 0.3 | 51.4 ± 0.3 | 49.9 ± 0.2
Hematological changes at 12 mo. | MCH (pg, mean ± SE) | 17 ± 0.1 | 16.8 ± 0.1 | 16.6 ± 0.1 | 16.2 ± 0.1 | 15.7 ± 0.1
| MCHC (mean ± SE) | 32.3 ± 0.2 | 32.1 ± 0.3 | 32.0 ± 0.2 | 31.6 ± 0.2 | 31.5 ± 0.2
| Hgb (mean ± SE, g/dL) | 15.8 ± 0.2 | 15.4 ± 0.2 | 15.6 ± 0.2 | 15.6 ± 0.2 | 15.3 ± 0.1
Hematological changes at 90 d | N | 10 | 10 | 10 | 10 | 10
| TWA Dose mg/kg-d (90 d) | 0 | 0.401 | 1.58 | 4.16 | 11.7
| Hgb (mean ± SE, g/dL) | 15.1 ± 0.1 | 14.9 ± 0.1 | 14.9 ± 0.2 | 14.6 ± 0.2 | 12.9 ± 0.2
Hematological changes at 22 d | N | 10 | 10 | 10 | 10 | 10
| TWA Dose mg/kg-d (22 d) | 0 | 0.634 | 2.49 | 6.67 | 17.7
| Hgb (mean ± SE, g/dL) | 15.5 ± 0.3 | 15.1 ± 0.2 | 14.2 ± 0.2 | 12.0 ± 0.3 | 10.1 ± 0.2

a Revised estimates for time weighted average daily doses calculated from NTP data. These may differ from the average doses presented elsewhere in this toxicological review, which are typically rounded or based on averages of fewer timepoints.

Table D-2 Noncancer endpoints selected for dose-response modeling for Cr(VI) (oral) from NTP (2007f)

Species/Sex endpoint | Doses and effect data
Rat/female | N | 10 | 10 | 10 | 10 | 10 | 10
Rat/female | Cr(VI) mg/L | 0 | 20 | 40 | 90 | 170 | 350
Liver changes at 90 d | TWA dose mg/kg-d ^a^ | 0 | 1.7 | 3.5 | 5.9 | 11.2 | 20.9
| ALT (mean ± SE, IU/L) | 64 ± 5 | 437 ± 68 | 218 ± 27 | 245 ± 30 | 246 ± 37 | 248 ± 22
Rat/male | N | 8 | 10 | 10 | 10 | 10 | 10
Rat/male | Cr(VI) mg/L | 0 | 20 | 40 | 90 | 170 | 350
Liver changes at 90 d | TWA dose mg/kg-d ^a^ | 0 | 1.7 | 3.5 | 5.9 | 11.2 | 20.9
| ALT (mean ± SE, IU/L) | 98 ± 6 | 274 ± 30 | 461 ± 102 | 447 ± 121 | 740 ± 81 | 191 ± 17
Rat/male; Hematological changes at 90 d | N | 10 | 10 | 10 | 10 | 10 | 10
Rat/male; Hematological changes at 90 d | TWA dose mg/kg-d ^a^ | 0 | 1.7 | 3.5 | 5.9 | 11.2 | 20.9
Rat/male; Hematological changes at 90 d | Hgb (mean ± SE, g/dL) | 15.3 ± 0.1 | 15.2 ± 0.1 | 15.0 ± 0.1 | 14.4 ± 0.2 | 13.3 ± 0.2 | 10.9 ± 0.3
Rat/male; Hematological changes at 23 d | N | 10 | 10 | 10 | 10 | 10 | 10
Rat/male; Hematological changes at 23 d | TWA dose mg/kg-d | 0 | 2.92 | 5.55 | 10.3 | 18.3 | 30.6
Rat/male; Hematological changes at 23 d | Hgb (mean ± SE, g/dL) | 15.9 ± 0.1 | 14.2 ± 0.2 | 12.0 ± 0.3 | 10.9 ± 0.3 | 10.3 ± 0.3 | 9.2 ± 0.3
Rat/female; Hematological changes at 90 d | N | 10 | 10 | 10 | 10 | 10 | 10
Rat/female; Hematological changes at 90 d | TWA dose mg/kg-d ^a^ | 0 | 1.7 | 3.5 | 5.9 | 11.2 | 20.9
Rat/female; Hematological changes at 90 d | Hgb (mean ± SE, g/dL) | 15.2 ± 0.1 | 15.4 ± 0.1 | 14.9 ± 0.1 | 14.3 ± 0.1 | 14.1 ± 0.2 | 12.0 ± 0.2
Rat/female; Hematological changes at 23 d | N | 10 | 9 | 8 | 9 | 10 | 9
Rat/female; Hematological changes at 23 d | TWA dose mg/kg-d | 0 | 2.97 | 5.56 | 9.83 | 17.7 | 30.9
Rat/female; Hematological changes at 23 d | Hgb (mean ± SE, g/dL) | 15.9 ± 0.1 | 14.7 ± 0.3 | 13.0 ± 0.3 | 11.8 ± 0.3 | 10.9 ± 0.2 | 9.7 ± 0.2

a These values are for both males and females at 14 weeks provided bv NTP (2007f). Alternatively, slightly different doses in mg/kg-d may be estimated from the NTP data: 1.74, 3.14, 5.93, 11.2, 20.9 for males, and 1.74, 3.49, 6.28, 11.5, 21.3 for females. For this assessment, the average value was applied to both male and female rats at 14 weeks. For data at 23 days, NTP did not provide time weighted average doses, so they were estimated from raw data. Sex-specific doses at 23 days are listed because they differ greatly at high drinking water concentration.

Table D-3 Noncancer endpoints selected for dose-response modeling for Cr(VI) (oral) from NTP (1997)

Species/sex endpoint | Doses and effect data
Mouse/female | TWA dose mg/kg-d | 0 | 11.6 | 24.4 | 50.6
F1 male pups PND14 | Pup weight g ± SE (N litters) | 7.95 ± 0.50 (15) | 7.69 ± 0.36 (13) | 7.51 ± 0.48 (12) | 6.93 ± 0.27 (16)
F1 male pups PND21 | Pup weight g ± SE (N litters) | 9.38 ± 0.64 (15) | 8.52 ± 0.59 (14) | 8.66 ± 0.63 (12) | 7.94 ± 0.34 (16)
F1 female pups PND14 | Pup weight g ± SE (N litters) | 7.71 ± 0.38 (15) | 7.85 ± 0.36 (15) | 8.05 ± 0.53 (13) | 7.04 ± 0.33 (18)
F1 female pups PND21 | Pup weight g ± SE (N litters) | 9.03 ± 0.55 (15) | 8.77 ± 0.55 (16) | 9.01 ± 0.68 (13) | 8.17 ± 0.42 (18)

TWA dose is for the female F0 (maternal) generation.

Table D-4 Gastrointestinal endpoints evaluated for dose-response modeling for Cr(VI) (oral) from NTP (2007f)

Species/sex endpoint | Doses and effect data
Mouse/female | N | 10 | 10 | 9 | 10 | 10 | 10
Mouse/female | Cr(VI) mg/L | 0 | 21.8 | 43.6 | 87.2 | 174.5 | 349
Diffuse epithelial hyperplasia (duodenum) at 90d | TWA dose mg/kg-d | 0 | 3.1 | 5.3 | 9.1 | 15.7 | 27.9
Diffuse epithelial hyperplasia (duodenum) at 90d | Incidence/N | 0/10 | 7/10 | 8/9 | 10/10 | 10/10 | 10/10
Mouse/male; Diffuse epithelial hyperplasia (duodenum) at 90d | N | 10 | 10 | 10 | 10 | 10 | 10
Mouse/male; Diffuse epithelial hyperplasia (duodenum) at 90d | Cr(VI) mg/L | 0 | 21.8 | 43.6 | 87.2 | 174.5 | 349
Mouse/male; Diffuse epithelial hyperplasia (duodenum) at 90d | TWA dose mg/kg-d | 0 | 3.1 | 5.3 | 9.1 | 15.7 | 27.9
Mouse/male; Diffuse epithelial hyperplasia (duodenum) at 90d | Incidence/N | 0/10 | 4/10 | 5/10 | 10/10 | 10/10 | 10/10

Table D-5 Gastrointestinal endpoints evaluated for dose-response modeling for Cr(VI) (oral) from Thompson et al. (2011b)

Species/sex endpoint | Doses and effect data
Mouse/female | N | 10 | 10 | 10 | 10 | 10 | 10 | 10
Mouse/female | Cr(VI) mg/L | 0 | 0.1 | 1.4 | 4.9 | 20.9 | 59.3 | 181
Crypt cell hyperplasia (duodenum) at 90 d | TWA dose mg/kg-d | 0 | 0.024 | 0.32 | 1.1 | 4.6 | 11.6 | 31.1
| Incidence/N | 0/10 | 0/10 | 0/10 | 0.10 | 0/10 | 9/10 | 9/10
Villous cytoplasmic vacuolization (duodenum) at 90 d | Incidence/N | 0/10 | 0/10 | 0/10 | 0/10 | 5/10 | 10/10 | 7/10

### D.1.1 Evaluation of Model Fit and Model Selection

Basic statistical background and guidance on choosing a model structure for the data being analyzed, fitting models, comparing models, and calculating confidence limits to derive a BMDL to use as a POD are outlined in EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012a), Sections 2.3.9 and 2.5. Empirical models that provide the best fit to the dose-response data are typically used in the absence of data to support development of a biologically based model. Although these models are empirical, parameters are typically constrained on some of them for the purposes of strengthening the biological plausibility of the results (i.e., many toxic effects exhibit a monotonic dose-response), and to prevent imprecise BMDs/BMDLs resulting from steeply supralinear models [(U.S. EPA, 2012a) §2.3.3.3]. Consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012a), initial runs of the log-probit model did not constrain the slope parameter, whereas initial runs of the gamma, dichotomous Hill, Weibull, and log-logistic models constrained their slope or power parameters to be ≥1. As noted in Benchmark Dose Software (BMDS) Version 3.2 User Guide (U.S. EPA, 2020a), some models with unrestricted coefficients can give more complicated shapes, in particular high-degree polynomial models (which produce unrealistic “wavy” results with negative response rates).

For each candidate endpoint/study the following steps were taken:

1) Goodness-of-fit was assessed for all models [(U.S. EPA, 2012a) §2.3.5].
  a. Models having a goodness-of-fit p-value of less than 0.1 were rejected.^7^
  b. Models not adequately describing the dose-response relationship (especially in the low-dose region) were rejected on the basis of examining the dose group-scaled residuals^8^ and graphs of models and data.
  The models that remained (after rejecting those that did not meet the recommended default statistical criteria for adequacy and fail in visual inspection of model fit) were used for determining the BMDL. The default selection criteria are listed below [(U.S. EPA, 2012a) §2.3.9]:
2) If the BMDL estimates from the remaining models were sufficiently close (generally defined as being within threefold, as in the case of this assessment), it was assumed there was no particular influence of the individual models on the estimates. In this case, the model with the lowest AIC was chosen.
3) If the BMDL estimates from the remaining models were not sufficiently close, it was assumed there was some model dependence (i.e., model uncertainty) of the estimate. In this case, if there was no clear remaining biological or statistical basis on which to choose among them, the lowest BMDL was selected as a reasonable conservative estimate (U.S. EPA (2012a)see Section 2.3.9).
4) In some cases, modeling attempts did not yield useful results. When this occurred, the NOAEL (or LOAEL) was used as a candidate POD.

Logfiles of BMD model outputs are contained in (U.S. EPA, 2021a).

#### D.1.1.1 Modeling issues related to diffuse epithelial hyperplasia in mice

Benchmark dose modeling did not result in useful results for diffuse epithelial hyperplasia in female mice from NTP (2008). Using BMDS (v 3.2), three models fit the full dataset adequately (based on goodness-of-fit p-value ≥ 0.10): dichotomous Hill, log-logistic, and log-probit. However, the log-probit model yielded a very low BMDL (150 times lower than the lowest nonzero dose of 0.302 mg/kg-day). Because the model fit was adequate compared with the other two models, it could not be excluded from model selection. The residuals for the log-probit result were sufficiently low, and its AIC was between that of the other two models (see below). Changing model parameter restrictions did not resolve the issue. It was concluded, based on the criteria outlined above in Section D.1.1 (criteria 3 and 4), that there was too much uncertainty in the BMD estimate to use these model results for determining the POD.

Table D-6 BMD model results for diffuse epithelial hyperplasia in female mice from NTP (2008) (no high doses omitted)

Model | BMR | BMD mg/kg-d | BMDL mg/kg-d | Goodness-of-fit p-value | AIC
Log-logistic | 10% ER | 0.0722 | 0.0530 | 0.1145 | 205.07
Log-probit | 10% ER | 0.0199 | 0.00199 | 0.3043 | 204.80
Dichotomous Hill | 10% ER | 0.0561 | 0.0268 | 0.4132 | 204.08

The lowest dose for female mice is 0.302 mg/kg-d.

The primary reason for the high uncertainty on the BMD estimate is that the response rate (38%) at the lowest dose was much higher than the BMR of 10% ER (the control group had 0% response). In addition, the data are supralinear and plateau at the three high doses (as the incidence approaches 100%).

Dropping high doses can address the supralinear shape and high-dose effect to achieve adequate model fit in the response region of interest. In this case, dropping the highest dose does not resolve the issue because the three high doses exhibit a flat response. However, omitting the two highest doses can achieve an optimal model fit within the set of models run (see below).

Table D-7 Modeling alternatives for diffuse epithelial hyperplasia in mice from NTP (2008)

Species/sex | Model | Doses dropped | BMR | BMD mg/kg-d | BMDL mg/kg-d
Mice/M | Quantal-linear | 1 | 10% ER | 0.148 | 0.121
Mice/F | Log-logistic | 0 | 10% ER | 0.0722 | 0.0530
| Dichotomous Hill | 0 | 10% ER | 0.0561 | 0.0268
| Log-probit | 0 | 10% ER | 0.0199 | 0.00199
| Quantal-linear | 2 | 10% ER | 0.0852 | 0.0672
| LOAEL | – | – | LOAEL = 0.302 | LOAEL/10 = 0.0302
| Dichotomous Model Avg. | 0 | 10% ER | 0.0431 | 0.00463
| Log-logistic | 0 | 30% ER | 0.278 | 0.204
| Dichotomous Hill | 0 | 30% ER | 0.200 | 0.110
| Log-probit | 0 | 30% ER | 0.130 | 0.0329
| | | | | BMDL/3 = 0.0110
| Dichotomous Model Avg. | 0 | 30% ER | 0.198 | 0.0708
| | | | | BMDL/3 = 0.0236

The lowest dose for female mice is 0.302 mg/kg-d.

Other approaches to address the modeling issues for this dataset include increasing the BMR to be closer to the lowest observed response rate (which would decrease the uncertainty on the BMD) or attempting alternative modeling (such as Dichotomous model averaging). Other statistical issues can arise when implementing these approaches (e.g., an additional uncertainty adjustment would be needed when increasing the BMR). Dichotomous model averaging (using BMDS 3.3.2) produces a result that is lower than the LOAEL/10 and raising the BMR to 30% did not produce an adequate result among the individual models. Because the BMDL_30_s varied significantly among the models with adequate fit, the lowest BMDL_30_ would be chosen (and if an adjustment is performed to approximate the 10% BMR, this value is lower than the LOAEL/10). Dichotomous model averaging at a BMR of 30% would produce a BMDL_30_/3 that is lower than LOAEL/10 (but somewhat closer to LOAEL/10 than other results). Note that adjusting the BMDL_30_ by 1/3 was done for comparative purposes only and is not a method used for RfD derivation (only adjustments by PBPK models, data derived extrapolation factors, uncertainty factors, or other standard units or dose adjustments are valid).

The LOAEL divided by a UF_L_ = 10 (the LOAEL-to-NOAEL uncertainty factor) produces a reasonable result when compared with the alternative BMDL_10_s. The value (0.0302 mg/kg-day) is within the bounds of the alternatives. At a BMR of 10%, LOAEL/10 is significantly higher than log-probit, 13% higher than dichotomous Hill, and 43% lower than log-logistic.

Table D-8 RfDs for modeling alternatives of diffuse epithelial hyperplasia in mice from NTP (2008)

Species/sex | Model | Doses dropped | BMR | BMDL or LOAEL mg/kg-d | Internal dose mg/kg-d | TWA BW kg | BW^3/4^ adjust | POD_HED_ mg/kg-d | Composite UF | RfD mg/kg-d
Mice/M | Quantal-linear | 1 | 10% ER | 0.121 | 0.0182 | 0.05 | 2.88 × 10^−3^ | 0.0443 | 10 | 4.43 × 10^−3^
Mice/F | Log-logistic | 0 | 10% ER | 0.0530 | 0.00792 | 0.05 | 1.25 × 10^−3^ | 0.0204 | 10 | 2.04 × 10^−3^
Mice/F | Dichotomous Hill | 0 | 10% ER | 0.0268 | 0.00400 | 0.05 | 6.32 × 10^−4^ | 0.0106 | 10 | 1.06 × 10^−3^
Mice/F | Log-probit | 0 | 10% ER | 0.00199 | 0.000296 | 0.05 | 4.68 × 10^−5^ | 7.95 × 10^−4^ | 10 | 7.95 × 10^−5^
Mice/F | Quantal-linear | 2 | 10% ER | 0.0672 | 0.0101 | 0.05 | 1.60e × 10^−3^ | 0.0258 | 10 | 2.58 × 10^−3^
Mice/F | LOAEL | – | – | 0.302 | 0.0463 | 0.05 | 7.32 × 10^−3^ | 0.0911 | 100 | 9.11 × 10^−4^

Mean and median value of log-logistic, log-probit, and dichotomous Hill results (with 0 doses dropped) is 1.06 × 10 ^3^ mg/kg-d.

#### D.1.1.2 Modeling issues related to chronic liver inflammation in female rats

An issue similar to that described above for hyperplasia also applied to data for chronic liver inflammation in female rats. The dose-response data exhibit a supralinear shape, leading to uncertainty in estimating the BMDL. Three adequately fitting models produced very different results, with one of them producing a BMDL that was over 75 times lower than the lowest dose.

Table D-9 BMD model results for chronic liver inflammation in female rats from NTP (2008)

Model | BMR | BMD mg/kg-d | BMDL mg/kg-d | Goodness-of-fit p-value | AIC
Log-logistic | 10% ER | 0.232 | 0.142 | 0.3871 | 312.44
Log-probit | 10% ER | 0.0546 | 0.00325 | 0.943 | 311.63
Dichotomous Hill | 10% ER | 0.107 | 0.0424 | 0.8962 | 311.73
Dichotomous model avg. | – | 0.366 | 0.0204 | – | –
LOAEL | – | LOAEL = 0.248 | – | – | –

The lowest dose in female rats was 0.248 mg/kg-d.

As with female mouse hyperplasia, there was too much uncertainty in the BMD estimate to use these model results for determining the POD. Dichotomous model averaging (using BMDS 3.3.2) produces a result that is still slightly lower than LOAEL/10.

Table D-10 RfDs for modeling alternatives of chronic liver inflammation in female rats from NTP (2008)

Model | BMR | BMDL or LOAEL mg/kg-d | Internal dose mg/kg-d | TWA BW kg | BW^3/4^ adjust | POD_HED_ mg/kg-d | Composite UF | RfD mg/kg-d
Log-logistic | 10% ER | 0.142 | 0.0109 | 0.260 | 2.60 × 10^−3^ | 0.0402 | 10 | 4.02 × 10^−3^
Log-probit | 10% ER | 0.00325 | 2.43 × 10^−4^ | 0.260 | 5.80 × 10^−5^ | 9.97 × 10^−4^ | 10 | 9.97 × 10^−5^
Dichotomous Hill | 10% ER | 0.0424 | 3.20 × 10^−3^ | 0.260 | 7.64 × 10^−4^ | 0.0128 | 10 | 1.28 × 10^−3^
LOAEL | – | 0.248 | 0.0195 | 0.260 | 4.66 × 10^−3^ | 0.0669 | 100 | 6.69 × 10^−4^

#### D.1.1.3 Modeling issues related to liver fatty changes in female rats

As shown in the table below, all models achieved an adequate fit. Dose-response data exhibit a supralinear shape, leading to uncertainty in estimating the BMDL. Dichotomous Hill and log-probit results were significantly different than the others. The model fits were adequate compared with the other models, and they could not be excluded from model selection. The log-probit BMDL was over 130 times lower than the lowest dose.

Table D-11 BMD model results for fatty change in liver of female rats from NTP (2008)

Model | BMR | BMD mg/kg-d | BMDL mg/kg-d | Goodness-of-fit p-value | AIC
Dichotomous Hill | 10% ER | 0.426 | 0.0117 | 0.911 | 239.410
Log-logistic | 10% ER | 1.953 | 1.105 | 0.394 | 240.375
Multistage Degrees 1–4 and Gamma, Weibull | 10% ER | 2.300 | 1.414 | 0.335 | 240.843
Logistic | 10% ER | 3.480 | 2.532 | 0.205 | 242.244
Log-probit | 10% ER | 0.342 | 0.00182 | 0.995 | 239.237
Probit | 10% ER | 3.325 | 2.387 | 0.217 | 242.074

The lowest dose in female rats was 0.248 mg/kg-d.

There was too much uncertainty in the BMD estimate to use these model results for determining the POD. The lowest dose was chosen as the NOAEL (less than 10% extra risk from control occurred at the lowest dose).

## D.2 BENCHMARK DOSE MODELING SUMMARY FOR CANCER ENDPOINTS

### D.2.1 Cancer Data for Dose-Response Modeling

For this assessment, dose-response modeling of endpoints for the oral route was performed on the basis of time-weighted average daily dose of Cr(VI), in mg/kg-day. This value could then be converted to an internal rodent dose, depending on the tissue or endpoint. The time-weighted average was calculated based on time-course dose data available through the data collection time for each endpoint.

The cancer endpoints selected for dose-response modeling are based on the data presented in Table D-19. For reference, historical control data from the National Toxicology Program encompassing the time period of the sodium dichromate dihydrate bioassays are presented in Table D-20. These were not used to make adjustments to the dose-response modeling data.

Datasets modeled were:

- Male mice bearing adenomas or carcinomas of the small intestine (duodenum, jejunum, or ileum)
- Female mice bearing adenomas or carcinomas of the small intestine (duodenum, jejunum, or ileum)
- Male rats bearing squamous cell carcinoma or papilloma (oral mucosa or tongue)
- Female rats bearing squamous cell carcinoma or papilloma (oral mucosa or tongue)

For each endpoint, the exposure doses and data used for the modeling are presented. The sample sizes were adjusted to be based on the number of animals surviving longer than one year. The incidences were based on the number of tumor-bearing animals. For example, a mouse with two tumors in the duodenum and one tumor in the jejunum is counted only once, and a rat with both a squamous cell carcinoma in the tongue and a squamous cell papilloma in the oral mucosa is counted once.

Table D-12 Data of neoplastic lesions in rats and mice (NTP, 2008)

Tumor type and species/sex | | Administered mg/L, mg/kg-d Cr(VI)^a^ and incidence/total
Male B6C3F1 mice | | 0 mg/L | 5 | 10 | 30 | 90
Male B6C3F1 mice | | 0 mg/kg-d | 0.450 | 0.914 | 2.40 | 5.70
Adenomas (duodenum) | | 1/50 | 0/50 | 1/50 | 5/50 | 15/50^*^
Carcinomas (duodenum) | | 0/50 | 0/50 | 0/50 | 2/50 | 3/50
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence/Total | 1/50 | 3/50 | 2/50 | 7/50^*^ | 20/50^*^
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence/Total (adj)^b^ | 1/50 | 3/49 | 2/49 | 7/50^*^ | 20/50^*^
Animals dead prior to d 365 | | 0 | 1 | 1 | 0 | 0
Female B6C3F1 mice | | 0 mg/L | 5 | 20 | 60 | 180
Female B6C3F1 mice | | 0 mg/kg-d | 0.302 | 1.18 | 3.24 | 8.89
Adenomas (duodenum) | | 0/50 | 0/50 | 2/50 | 13/50^*^ | 12/50^*^
Carcinomas (duodenum) | | 0/50 | 0/50 | 0/50 | 1/50 | 6/50^*^
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence/Total | 1/50 | 1/50 | 4/50 | 17/50^*^ | 22/50^*^
Adenomas or carcinomas (duodenum, jejunum, or ileum) | Incidence/Total (adj)^b^ | 1/49 | 1/50 | 4/49 | 17/50^*^ | 22/49^*^
Animals dead prior to d 365 | | 1 | 0 | 1 | 0 | 1
Male F344 rats | | 0 mg/L | 5 | 20 | 60 | 180
Male F344 rats | | 0 mg/kg-d | 0.200 | 0.796 | 2.10 | 6.07
Squamous cell carcinoma (oral mucosa) | | 0/50 | 0/50 | 0/49 | 0/50 | 6/49^*^
Squamous cell papilloma (oral mucosa) | | 0/50 | 0/50 | 0/49 | 0/50 | 1/49
Squamous cell carcinoma (tongue) | | 0/49 | 1/50 | 0/47 | 0/49 | 0/48
Squamous cell papilloma (tongue) | | 0/49 | 0/50 | 0/47 | 0/49 | 1/48
Squamous cell carcinoma or papilloma (oral mucosa or tongue) | Incidence/Total | 0/50 | 1/50 | 0/49 | 0/50 | 7/49^*^
Squamous cell carcinoma or papilloma (oral mucosa or tongue) | Incidence/Total (adj)^b^ | 0/50 | 1/47 | 0/47 | 0/50 | 7/49^*^
Animals dead prior to d 365 | | 0 | 3 | 2 | 0 | 0
Female F344 rats | | 0 mg/L | 5 | 20 | 60 | 180
Female F344 rats | | 0 mg/kg-d | 0.248 | 0.961 | 2.60 | 7.13
Squamous cell carcinoma (oral mucosa) | | 0/50 | 0/50 | 0/50 | 2/50 | 11/50^*^
Squamous cell carcinoma (tongue) | | 0/45 | 0/49 | 0/48 | 1/48 | 0/48
Squamous cell papilloma (tongue) | | 1/45 | 1/49 | 0/48 | 0/48 | 0/48
Squamous cell carcinoma (oral mucosa or tongue) | Incidence/Total | 1/50 | 1/50 | 0/50 | 2/50 | 11/50^*^
Squamous cell carcinoma (oral mucosa or tongue) | Incidence/Total (adj)^b^ | 1/50 | 1/50 | 0/50 | 2/50 | 11/50^*^
Animals dead prior to d 365 | | 0 | 0 | 0 | 0 | 0

a Time-weighted average daily doses calculated from NTP water consumption data.

b Tumor incidences adjusted based on the number of animals surviving beyond 365 days. First tumor onset: 451 days for intestinal tumors in mice, and 506 days for oral tumors in rats (both occurring at the highest doses).

* Denotes significant difference from the control group reported by NTP (2008) using the Poly-3 test (p < 0.05).

Table D-13 NTP historical control data for animals fed the NTP-2000 diet, from studies of all routes and vehicles of administration (incidence, %, mean % ± standard deviation %)^a^

| Male B6C3F1 mice | Female B6C3F1 mice | Male F344/N rats | Female F344/N rats
Adenomas
Duodenum | 8/1499 (0.53%) 0.55% ± 1.20% | 3/1598 (0.19%) 0.19% ± 0.56% | – | –
Jejunum | 1/1499 (0.07%) 0.07% ± 0.36% | 0/1598 (0.00%) 0.00% ± 0.00% | – | –
Ileum | – | – | – | –
SI unspecified | 9/1499 (0.60%) 0.62% ± 1.20% | 3/1598 (0.19%) 0.19% ± 0.56% | – | –
Carcinomas
Duodenum | 3/1499 (0.20%) 0.21% ± 0.79% | 1/1598 (0.06%) 0.06% ± 0.35% | – | –
Jejunum | 25/1499 (1.67%) 1.69% ± 1.83% | 4/1598 (0.25%) 0.23% ± 0.57% | 1/1449 (0.07%) 0.07% ± 0.37% | 0/1350 (0.00%) 0.00% ± 0.00%
Ileum | 2/1499 (0.13%) 0.14% ± 0.50% | 2/1598 (0.13%) 0.13% ± 0.48% | – | –
SI unspecified | 30/1499 (2.00%) 2.03% ± 1.81% | 7/1598 (0.44%) 0.42% ± 0.70% | 1/1449 (0.07%) 0.07% ± 0.37% | 0/1350 (0.00%) 0.00% ± 0.00%
Adenomas or carcinomas
SI unspecified | 38/1499 (2.54%) 2.59% ± 2.26% | 10/1598 (0.63%) 0.61% ± 0.90% | 1/1449 (0.07%) 0.07% ± 0.37% | 0/1350 (0.00%) 0.00% ± 0.00%
| Male B6C3F1 mice | Female B6C3F1 mice | Male F344/N rats | Female F344/N rats
Squamous cell carcinomas
Oral mucosa | 1/1499 (0.07%) 0.07% ± 0.36% | 2/1598 (0.13%) 0.13% ± 0.48% | 5/1449 (0.35%) 0.32% ± 0.66% | 5/1350 (0.37%) 0.38% ± 0.72%
Tongue | 1/1499 (0.07%) 0.07% ± 0.36% | 4/1598 (0.25%) 0.26% ± 0.63% | 0/1449 (0.00%) 0.00% ± 0.00% | 2/1350 (0.15%) 0.15% ± 0.52%
Oral cavity^b^ | 2/1499 (0.13%) 0.14% ± 0.50% | 6/1598 (0.38%) 0.39% ± 0.71% | 5/1449 (0.35%) 0.32% ± 0.66% | 7/1350 (0.52%) 0.54% ± 0.95%
Squamous cell papillomas
Oral mucosa | 1/1499 (0.07%) 0.03% ± 0.18% | 0/1598 (0.00%) 0.00% ± 0.00% | 1/1449 (0.07%) 0.07% ± 0.37% | 2/1350 (0.15%) 0.15% ± 0.52%
Tongue | 1/1499 (0.07%) 0.07% ± 0.36% | 2/1598 (0.13%) 0.13% ± 0.48% | 4/1449 (0.28%) 0.25% ± 0.60% | 5/1350 (0.37%) 0.38% ± 0.91%
Oral cavity^b^ | 2/1499 (0.13%) 0.10% ± 0.40% | 2/1598 (0.13%) 0.13% ± 0.48% | 5/1449 (0.35%) 0.32% ± 0.66% | 7/1350 (0.52%) 0.54% ± 0.95%
Squamous cell carcinomas or papillomas squamous
Tongue | 2/1499 (0.13%) 0.14% ± 0.50% | 6/1598 (0.38%) 0.39% ± 0.87% | 4/1449 (0.28%) 0.25% ± 0.60% | 7/1350 (0.52%) 0.54% ± 1.10%
Oral cavity^b^ | 4/1499 (0.27%) 0.24% ± 0.59% | 8/1598 (0.50%) 0.52% ± 0.91% | 10/1449 (0.69%) 0.64% ± 0.78% | 14/1350 (1.04%) 1.08% ± 1.58%

a March 2007 historical control reports for F344/N rats and B6C3F1 mice (NTP, 2007a, b, c, d). Control data encompass chronic studies that include the NTP sodium dichromate dihydrate study. Denominator is number of animals necropsied.

b Oral mucosa, tongue, pharynx, tooth, gingiva. Note: for oral cavity, papilloma includes both papilloma squamous and papillomas.

### D.2.2 Evaluation of Model Fit and Model Selection

Following EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012a) Sections 2.3.9 and 2.5 and EPA’s Choosing Appropriate Stage of a Multistage Model for Cancer Modeling (U.S. EPA, 2014a):

1) All orders of the Multistage model up to two less than the number of dose groups were fit (e.g., up to model order k−2 if there are k dose groups).
  a. If all parameter (γ, β1, …, βk-2) estimates were positive, the model with the lowest AIC was chosen as the best-fitting model if at least one of the models provides an adequate fit to the data. Consistent with EPA’s guidance when there is an a priori reason to prefer a specific model(s) [(U.S. EPA, 2012a) §2.3.5 and §2.3.9], Multistage models having a goodness-of-fit p-value of less than 0.05 were rejected.
  b. Otherwise (i.e., if any parameter is estimated to be zero and is thus at a boundary), the following procedure (2) was followed:
2) Model fits of orders 1 and 2 (linear and quadratic, respectively) were examined for adequate fit. The linear model parameters (γ, β1), and the quadratic model parameters (γ, β1, β2) were examined.
  a. If only one of the models exhibited adequate fit, that model was chosen.
  b. If both models exhibited adequate fit:
    i) The model with the lowest AIC was chosen if all of the parameters (γ, β1,and β2) were positive.
    ii) Otherwise, the model with the lower BMDL (more health protective) was chosen. If the BMD/BMDL ratio is larger than 3, the matter was referred to EPA statisticians and health assessors for a decision.

For this assessment, model fit of order 1 was selected for all endpoints. Logfiles of BMD model outputs are contained in (U.S. EPA, 2021a).

## D.3 ALTERNATIVE APPROACHES FOR CANCER AND NONCANCER DOSE-RESPONSE ASSESSMENT

### D.3.1 Noncancer Oral Dose-response Applying Default BW^3/4^ Scaling Approaches

As a comparison against the pharmacokinetic method, RfDs were calculated using default BW^3/4^ scaling. However, this comparison applies UF_H_ = 3 (removing the pharmacokinetic portion of the intraindividual variability). By not accounting for Cr(VI) reduction in either the rodent (gastric pH = 4.5) or the human (gastric pH = 1.3), the default scaling approach focuses on a sensitive population in terms of pharmacokinetics (i.e., a human population where baseline gastric pH = 4.5, and gastric juice reduction capacity is equivalent to that of the rodent). All uncertainty factors are described in Section 4. Study-specific body weights (and not default animal body weights) are used in order to make a direct comparison of default and PBPK methods (which relied on study-specific body weight).

Table D-14 Summary of derivation of points of departure following oral exposure for effects outside of the gastrointestinal tract (default approach)

Species/sex | Model | BMR | BMD mg/kg-d | BMDL mg/kg-d | TWA BW (kg) | POD_HED_ mg/kg-d^a^
Diffuse epithelial hyperplasia of the duodenum at 2 yr ( NTP, 2008 )
Mice/M | Quantal-linear^b^ | 10 | 0.148 | 0.121 | 0.05 | 0.0191
Mice/F | LOAEL | – | – | 0.302 | 0.05 | 0.0478
Changes in the liver enzyme alanine aminotransferase (ALT) ( NTP, 2008 )
Rat/M 12 mo. | Exp2^b^ | 1RD | 1.83 | 1.56 | 0.395 | 0.414
Rat/M 3 mo. | NOAEL | – | – | 1.58 | 0.246 | 0.372
Changes in the liver enzyme alanine aminotransferase (ALT) at 90 d ( NTP, 2007f )
Rat/M | LOAEL | – | – | 1.74 | 0.232 | 0.404
Rat/F | LOAEL | – | – | 1.74 | 0.160 | 0.368
Chronic inflammation at 2 yr ( NTP, 2008 )
Rat/F | LOAEL | – | – | 0.248 | 0.260 | 0.0592
Mice/F | Log-logistic | 10% ER | 3.70 | 1.33 | 0.05 | 0.210
Liver fatty change at 2 yr ( NTP, 2008 )
Rat/F | NOAEL | – | – | 0.248 | 0.260 | 0.0592
Decreased offspring growth ( NTP, 1997 )
Mouse/F | NOAEL | – | – | 11.6 | 0.024 | 1.53
Decreased hemoglobin (Hb) ( NTP, 2008 )
Rat/M (22 d) | Exp-4 | 1SD | 1.07 | 0.816 | 0.138 | 0.166

a BW^3/4^ scaling adjustment: mg/kg-day multiplied by (BW_A_/80)^1/4^). Animal BW set to study/sex-specific time weighted average values for hybrid PBPK modeling/BW^3/4^ scaling approach to maintain consistency with bioassay PBPK simulation.

b Data were amenable to BMD modeling with the highest dose omitted.

Table D-15 Effects and corresponding derivation of candidate values from PODs applying BW^¾^ scaling

Endpoint and reference | POD_HED_ (mg/kg-d) | POD Type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (mg/kg-d)
Gastrointestinal
Mouse (M) hyperplasia (NTP, 2008) | 0.0191 | BMDL_10_ | 3 | 3 | 1 | 1 | 1 | 10 | 1.91 × 10^−3^
Mouse (F) hyperplasia (NTP, 2008) | 0.0478 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 4.78 × 10^−4^
Liver
Rat (M) liver ALT (12 mo) (NTP, 2008) | 0.414 | BMDL_1RD_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0414^a^
Rat (M) liver ALT (3 mo) (NTP, 2008) | 0.372 | NOAEL | 3 | 3 | 1 | 3 | 1 | 30 | 0.0124^a^
Rat (M) liver ALT (90 d) (NTP, 2007f) | 0.404 | LOAEL | 3 | 3 | 10 | 3 | 1 | 300 | 1.35 × 10^−3a^
Rat (F) liver ALT (90 d) (NTP, 2007f) | 0.368 | LOAEL | 3 | 3 | 10 | 3 | 1 | 300 | 1.23 × 10^−3a^
Rat (F) liver chronic inflammation (2 yr) (NTP, 2008) | 0.0592 | LOAEL | 3 | 3 | 10 | 1 | 1 | 100 | 5.92 × 10^−4^
Mouse (F) liver chronic inflammation (2 yr) (NTP, 2008) | 0.210 | BMDL_10_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0210^a^
Rat (F) liver fatty change (2 yr) (NTP, 2008) | 0.0592 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 5.9 × 10^−3^
Developmental
Mouse (F) decreased offspring growth (NTP, 1997) | 1.53 | NOAEL | 3 | 3 | 1 | 1 | 1 | 10 | 0.153^a^
Hematological
Rat (M) decreased Hb (22 d) (NTP, 2008) | 0.166 | BMDL_1SD_ | 3 | 3 | 1 | 1 | 1 | 10 | 0.0166^a^

a Denotes values that are higher than RfDs derived from pharmacokinetic modeling.

RfDs derived from the pharmacokinetic modeling are more health-protective than BW^3/4^ scaling at high doses. This is because at high doses, the model is less sensitive to gastric pH and more sensitive to gastric reducing capacity. The assumed human variability in gastric reducing capacity is very high, causing the lower 1% prediction to ultimately produce a value lower than BW^3/4^ scaling. At low doses, the model is more sensitive to gastric pH. The BW^3/4^ method is essentially assuming that the human gastric pH > 4 (whereas the pharmacokinetic model assumes the human gastric pH = 1.3). As a result, the effectiveness of human gastric reduction when compared with the rodent has a stronger impact on the model at low doses and produces less health-protective RfDs.

### D.3.2 Uncertainty Assessment of Low-dose Extrapolation Method for Oral Cancer Dose-response

Because a mutagenic mode of action for Cr(VI) carcinogenicity (see Section 3.2.3) is “sufficiently supported in (laboratory) animals” and “relevant to humans,” EPA used a linear low dose extrapolation from the POD in accordance with Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a). However, multiple modes of action for tumor formation in the mouse small intestine could be occurring in parallel, and presenting different approaches may shed light on uncertainties in the assessment (U.S. EPA, 2005a). For comparative purposes, a nonlinear estimate is provided using a reference value approach based on one of the other modes of action outlined in Section 3.2.3 (hyperplasia being a key event or precursor to tumor development).

The dose-response relationships for diffuse epithelial hyperplasia in the small intestine of male and female mice from the chronic NTP (2008) bioassay was more sensitive than the dose-responses for adenomas and carcinomas in the same tissue (see Figure D-2). The nonlinear dose-response approach would assume the noncancer organ-specific reference dose for gastrointestinal toxicity (based on hyperplasia dose-response presented in Section 4.1) is protective of tumors in the small intestine: 9 × 10^−4^ mg/kg-day.

Figure D-2 Dose-response data for tumors and diffuse epithelial hyperplasia of the mouse small intestine (SI) and tumors of the rat oral cavity.

Applying the lifetime OSF for oral tumors of 0.27 risk per mg/kg-day, the oral dose for 1/10,000^9^ risk would be 0.0001/0.27 = 3.7 × 10^−4^ mg/kg-day. The nonlinear, RfD-based estimate (9 × 10^−4^ mg/kg-day) is 2.4 × higher. On the basis of the OSF, there would be a 9 × 10^−4^ mg/kg-day × 0.27 risk/(mg/kg-d) = 2.4/10,000 increased cancer risk at the dose estimated using the nonlinear, RfD-based approach.

Applying the adult-based OSF for oral tumors (0.16 per mg/kg-d), the oral dose for 1/10,000 risk would be 0.0001/0.16 = 6.25 × 10^−4^ mg/kg-day. On the basis of this adult value of the OSF, there would be a 9 × 10^−4^ mg/kg-day × 0.16 risk/(mg/kg-d) = 1.4/10,000 increased cancer risk at the dose estimated using the nonlinear, RfD-based approach.

For tumors of the mouse small intestines and male rat oral cavity, the dose-response was less sensitive than that for oral tumors in female rats (see Sections 3.2.3 and 4.1). The adult-based OSF for these other tumor endpoints is 0.1 risk per mg/kg-day (see Section 4.3.3), and the ADAF-adjusted lifetime OSF^10^ would be 0.17 risk per mg/kg-day. For this tumor type, the oral dose for 1/10,000 risk would be 5.9 × 10^−4^ mg/kg-day. The RfD-based estimate is 1.5× higher than this dose. Applying that OSF, there would be approximately a 9 × 10^−4^ mg/kg-day × 0.17 risk/(mg/kg-d) = 1.5/10,000 increased cancer risk at the dose estimated using the RfD-based approach.

## D.4 EXCLUSION OF HUMAN STUDIES FOR EXPOSURE-RESPONSE

Table D-16 Overview of studies excluded for exposure-response analysis of upper respiratory tract (nasal) effects in humans

Study | Population or industry | Reason(s) for exclusion
Armienta-Hernández and Rodríguez-Castillo (1995) | General population & chromate production | Air data and nasal effects data not contained in study, and source of data not cited.
Bloomfield and Blum (1928) | Electroplating | Cannot determine accuracy or precision of air concentration measurements.
Ceballos et al. (2019) [related study: Ceballos et al. (2017)] | Paint stripping/aircraft refinishing | Air concentration data not representative of inhaled dose due to full face mask use by exposed workers.
Elhosary et al. (2014) | Cement and tannery facilities | No air concentration data. Cannot determine if exposure was to Cr(VI) or Cr(III).
Fagliano et al. (1997) | Residential (soil) | No air concentration data. Cannot determine if exposure was to Cr(VI) or Cr(III).
Gomes (1972) | Electroplating | Relationship between air concentration and outcome cannot be estimated from presented data.
Horiguchi et al. (1990) | Electroplating | No air measurements.
Kitamura et al. (2003) | Electroplating | Did not include the preferred nasal outcome measurements.
Kleinfeld and Rosso (1965) | Electroplating | Relationship between air concentration and outcome cannot be estimated from presented data. Cannot determine accuracy or precision of air concentration measurements.
Korallus et al. (1982) | Chromate production | No air measurements.
Lee and Goh (1988) | Electroplating | No air measurements.
Lin et al. (1994) | Electroplating | Measurement only for total chromium in air, hexavalent chromium preferred.
Lucas and Kramkowski (1975) | Electroplating | Single exposure group.
Lucas (1976) | Painting/varnishing | Single exposure group, coexposures, did not include the preferred nasal outcome measurements.
Machle and Gregorius (1948) | Chromate production | Relationship between air concentration and outcome unable to be estimated from results as they are presented.
Mancuso (1951) | Chromate production | Measurement only for total chromium in air, hexavalent chromium preferred.
PHS (1953) | Chromate production | Relationship between air concentration and outcome cannot be estimated from presented data.
Royle (1975b) | Electroplating | Relationship between air concentration and outcome cannot be estimated from presented data.
Singhal et al. (2015) | Chromate production and electroplating | No air measurements.
Sorahan et al. (1998) [related: Sorahan et al. (1987)] | Ni-Cr platers | Relationship between air concentration and outcome cannot be estimated from presented data.
Vigliani and Zurlo (1955) | Chromate production and electroplating | No description of methods.
Wang et al. (1994) | Ferrochromium production | No air measurements.
Yuan et al. (2016) | Children in school near electroplating plants | Did not include the preferred nasal outcome measurements.

Note: Some studies excluded for consideration of nasal dose-response assessment were still included in the IRIS assessment for other hazards. For some institutional references (e.g., NIOSH reports), the primary investigators or report editors are listed as the authors.

Table D-17 Overview of studies excluded for exposure-response analysis of lung cancer in humans based on screening studies for adequate exposure-response data^a^

Reference | Reason for exclusion
Ahn and Jeong (2014) | Not an occupational study of chromium exposure and cancer; purpose was not to estimate a measure of relative risk.
Alderson et al. (1981) | Exposure assignments were based on tasks/ job title, not chromium measurements. No air sampling was described.
Alexander et al. (1996) | Cumulative exposure estimated using approach with high likelihood of exposure misclassification and lack of confidence in its representation of exposure to individual participants. Median follow-up for most of the cohort was less than 10 yr and median age at end of study was 42 yr, which reduced the ability to ascertain cancer deaths.
Armienta-Hernández and Rodríguez-Castillo (1995) | No air data.
Becker et al. (1985) | Group-level exposure assignments were based on tasks/ job title, not chromium measurements. No air sampling was described.
Beveridge et al. (2010) | Group-level exposure assignments were based on job title, not chromium measurements. No air sampling was described.
Bidstrup (1951) | Chromium exposures were not individually assigned; no measures of association provided. No air sampling was described.
Bidstrup and Case (1956) | Exposure assignments were based on tasks/ job title, not chromium measurements. No air sampling was described.
Blot et al. (2000) | Exposure metrics were not based on air measurements.
Boffetta et al. (2010) | Not an occupational study of chromium exposure and cancer; purpose was not estimating a measure of relative risk.
Brown et al. (2004) | No effect estimates were reported for lung cancer and chromium exposure.
Chatham-Stephens et al. (2013) | Not an epidemiological study. No outcome measurements. Risk assessment was performed.
Cole and Rodu (2005) | Not an epidemiological study (meta-analysis).
Davies et al. (1991) | Group-level exposure assignments were based on job title, not chromium measurements.
Franchini et al. (1983) | No air data.
Frentzel-Beyme (1983) | Group-level exposure assignments were based on job title, not chromium measurements. No air sampling was described.
Girardi et al. (2015) | Exposure metrics were not based on air measurements.
Halasova et al. (2009) | Inadequate exposure information.
Hall et al. (2020) ^b^ | Group-level exposure assignments were based on tasks/ job title, not chromium measurements. No air sampling was described.
Hayes et al. (1989) | Group-level exposure assignments were based on job title, not chromium measurements. No air sampling was described.
Hill and Ferguson (1979) | Analysis of trends over time; no analyses of associations with exposure metrics based on air measurements.
Johnson et al. (2011) | Ecological study with biomarker data and no air data.
Koh et al. (2011); Koh et al. (2013) | Inadequate exposure information.
Linos et al. (2011) | Ecological study with no air data.
Milatou-Smith et al. (1997) Sjögren et al. (1987) | Group-level exposure assignments were based on job tasks, not chromium measurements. No air sampling was described.
Moulin et al. (1993b) | Group-level exposure assignments were based on job tasks, not chromium measurements. No air sampling was described.
Moulin et al. (1993a) | No chromium measurements.
Moulin et al. (1990) | No chromium measurements.
NJ DEP (2008) | Relationship between air concentration and outcome cannot be estimated from presented data.
Pesch et al. (2019) | Exposures were based on tasks/ job title and air concentrations that were not from this study population/location.
Rafnsson et al. (1997) | Group-level exposure assignments were based on job tasks and duration of job, not chromium measurements.
Rosenman and Stanbury (1996) | Group-level exposure assignments were based on occupation, not chromium measurements. No air sampling was described.
Royle (1975a) | Inadequate exposure information. This article is part 1 of 2 articles. Air sampling was described in part 2, and concentrations were reported as exceeding certain values, but measured concentrations were not reported.
Shixiong (1994) | Categorical control data.
Sorahan and Harrington (2000) | Group-level exposure assignments were based on occupation, not chromium measurements. No air sampling was described.
Sorahan et al. (1987) | Group-level exposure assignments were based on occupation, not chromium measurements. No air sampling was described.
Sorahan et al. (1998) | Group-level exposure assignments were based on occupation, not chromium measurements. No air sampling was described.
Taylor (1966) | No chromium measurements.
van Wijngaarden et al. (2004) | Not an epidemiological study (meta-analysis).
TOMA (1987) | No chromium measurements.
Yang et al. (2013) | Not an epidemiological study (review).
Zhivin et al. (2013) | Exposure assignments were qualitative; based on time and numeric score for level, not chromium measurements.

a These studies were obtained via title/abstract screening and backward bibliography searches. Studies were excluded from consideration after full-text screening based on the rationale provided. In HERO (click here (https://hero.epa.gov/hero/index.cfm/project/page/project_id/2233)), these studies contain multiple inclusion/exclusion tags due to their potential relevance to other health effects. All were excluded from consideration for the lung cancer exposure-response.

b Laryngeal cancer (respiratory tract outside of the lung).

Table D-18 Overview of studies excluded for exposure-response analysis of lung cancer in humans based on screening the most recent analyses

Reference | Reason for exclusion
Mancuso (1997); Mancuso and Hueper (1951); Crump et al. (2003); Luippold et al. (2003) | Painesville Ohio cohort studies superseded by Proctor et al. (2016)
Hayes et al. (1979); Braver et al. (1985); Park et al. (2004); Park and Stayner (2006) | Baltimore Maryland cohort studies superseded by (Gibb et al., 2000b; 2015; 2020)
Korallus et al. (1982); Korallus et al. (1993) | German cohort studies superseded by Birk et al. (2006)
Pastides et al. (1994) | Castle Hayne, North Carolina cohort superseded by Luippold et al. (2005)
Machle and Gregorius (1948) | Baltimore and Painesville cohort studies superseded by Proctor et al. (2016) and (Gibb et al., 2015; 2020)

Table D-19 Overview of studies excluded for exposure-response analysis of lung cancer in humans

Reference | Reason for exclusion
Luippold et al. (2005) | SMR analysis conducted where no slope or standard error were produced or could be calculated based on published data.
AEI (2002) | SMR analysis conducted where no slope or standard error were produced or could be calculated based on published data.

Note: These studies had passed the initial full-text screening (despite inadequacies in exposure data) because they contained quantitative analyses that warranted further review for consideration. Studies were excluded from consideration after review of the quantitative methods and their utility for the exposure-response assessment.

## D.5 INDIVIDUAL-LEVEL ANALYSIS OF NEOPLASTIC AND NONNEOPLASTIC LESIONS IN MICE FROM NTP (2008)

Table D-20 Individual-level overview of neoplastic and nonneoplastic lesions in male mice from NTP (2008)

| | Tumors | | | Hyperplasia
ID | Cr(VI) (mg/L) | Duod | Jej | Il | Duod | Jej | Il
11 | 0 | A | – | – | – | – | –
55 | 5 | – | C (multi) | – | – | – | –
64 | 5 | – | – | A | – | – | –
81 | 5 | – | C | – | DE | LT | –
105 | 10 | – | – | C | DE | LT | CY
140 | 10 | A | – | – | – | – | –
155 | 30 | A | – | – | DE | – | –
161 | 30 | A, C | – | – | DE | LT | –
162 | 30 | – | C | – | DE | – | –
165 | 30 | A | – | – | DE | LT | –
167 | 30 | A | – | – | DE | – | –
172 | 30 | C | – | – | DE | LT
173 | 30 | A | – | – | DE | – | –
202 | 90 | – | C | – | DE | DE | –
203 | 90 | – | A | – | – | – | No eval
205 | 90 | C | – | – | DE | – | –
206 | 90 | A | – | – | DE | – | –
211 | 90 | – | C | – | DE | – | –
214 | 90 | A (multi) | – | – | DE | – | –
215 | 90 | A, C | A | – | DE | – | –
217 | 90 | A | – | – | – | – | –
218 | 90 | A (multi) | – | – | – | – | –
219 | 90 | A (multi) | – | – | DE | – | LT
222 | 90 | A | – | – | DE | – | –
223 | 90 | A | – | – | DE, FE | – | –
227 | 90 | A | No eval | – | – | No eval | –
234 | 90 | – | A | – | DE | – | –
235 | 90 | A (multi) | – | – | DE | LT | –
238 | 90 | A (multi) | – | – | DE | – | –
240 | 90 | A | – | – | – | No eval | No eval
242 | 90 | A, C | – | – | – | – | –
245 | 90 | A | – | – | – | – | –
249 | 90 | A (multi) | – | – | DE | – | –

Duod = duodenum, Jej = jejunum, Il = ileum; A = adenoma, C = carcinoma, LT = lymphoid tissue hyperplasia, DE = diffuse epithelial hyperplasia, FE = focal epithelial hyperplasia, CY = cyst.

Shaded rows correspond to exposed animals with no observed intestinal hyperplasia.

Table D-21 Individual-level overview of neoplastic and nonneoplastic lesions in female mice from NTP (2008)

| | Tumors | | | Hyperplasia
ID | Cr(VI) (mg/L) | Duod | Jej | Il | Duod | Jej | Il
268 | 0 | – | C | – | – | – | –
317 | 5 | – | A | – | – | – | –
351 | 20 | – | C | – | DE | LT | –
371 | 20 | A | – | – | DE, FE | DE | –
379 | 20 | A | – | – | DE | – | –
380 | 20 | – | C | – | DE | – | –
408 | 60 | A | – | – | DE | – | –
411 | 60 | A | – | – | – | – | –
412 | 60 | A | – | – | DE | LT | –
413 | 60 | A (multi) | – | – | DE | – | –
415 | 60 | A | – | – | DE, CY | LT | –
416 | 60 | – | A | – | – | – | –
420 | 60 | – | A | – | DE, FE | – | –
421 | 60 | A | C | – | DE | – | –
423 | 60 | A | – | – | DE | – | –
427 | 60 | A | – | – | – | – | –
428 | 60 | A | – | – | – | – | –
431 | 60 | A | – | – | DE | – | –
438 | 60 | C | – | – | DE | – | –
439 | 60 | – | C | – | DE | – | –
440 | 60 | A | – | – | DE | – | –
446 | 60 | A | – | – | DE | – | –
450 | 60 | A | – | – | – | – | –
451 | 180 | A | – | – | DE | – | –
452 | 180 | A (multi) | – | – | DE | – | –
454 | 180 | – | A | – | DE | DE | –
455 | 180 | A (multi) | A | – | DE | DE | –
458 | 180 | A | – | – | DE | – | –
459 | 180 | C | – | – | – | – | –
461 | 180 | – | A | – | DE | DE | –
466 | 180 | – | C | – | DE, LT | – | –
470 | 180 | C | – | – | DE | – | –
472 | 180 | – | A | – | DE | DE | –
474 | 180 | C | – | – | DE | DE | –
475 | 180 | A (multi) | – | – | DE | – | –
486 | 180 | – | A (multi) | – | DE | – | –
488 | 180 | A (multi) | – | – | DE | – | –
489 | 180 | A | – | – | DE | – | –
490 | 180 | A | – | – | DE | – | –
492 | 180 | C | – | – | DE | – | –
495 | 180 | A (multi) | – | – | DE | – | –
496 | 180 | A, C | – | – | DE | DE | –
497 | 180 | A | – | – | DE | – | –
498 | 180 | A (multi) | – | – | DE | – | –
499 | 180 | C | – | – | [dilation] | – | –

Duod = duodenum, Jej = jejunum; Il = ileum, LT = lymphoid tissue hyperplasia, DE = diffuse epithelial hyperplasia, FE = focal epithelial hyperplasia, CY = cyst.

Shaded rows correspond to exposed animals with no observed intestinal hyperplasia.

Table D-22 Summary of neoplastic and nonneoplastic lesions in mice from NTP (2008)

Concentration (mg/L) | Sex | Total # animals with tumors in the small intestine | # animals with tumors in the small intestine and no nonneoplastic lesions^a^ in the small intestine | Animal IDs
0 | M + F | 2 | 2 (100%) | 11, 268
5 | M + F | 4 | 3 (75%) | 55, 64, 317
10 | M | 2 | 1 (50%) | 140
20 | F | 4 | 0
30 | M | 7 | 0
60 | F | 17 | 5 (29.4%) | 411, 416, 427, 428, 450
90 | M | 20 | 7 (35%) | 203, 217, 218, 227, 240, 242, 245
180 | F | 22 | 2 (9.1%) | 459, 499
All (excluding control) | M + F | 76 | 18 (23.7%)

a Nonneoplastic lesions considered: lymphoid tissue hyperplasia, diffuse epithelial hyperplasia, focal epithelial hyperplasia, cyst. Full individual-level datasets are available from NTP (2007e).

## D.6 PROBABILITY DISTRIBUTIONS OF HUMAN EQUIVALENT DOSE FOR CANCER AND NONCANCER PODS DERIVED FROM TOXICOKINETIC MODELING

### D.6.1 Noncancer Model Outputs

Figure D-3 Model outputs and distribution for rat (M) liver ALT (3 months) (NTP, 2008).

Figure D-4 Model outputs and distribution for rat (F) liver ALT (90 days) (NTP, 2007f).

Figure D-5 Model outputs and distribution for rat (M) liver ALT (90 days) (NTP, 2007f)

Figure D-6 Model outputs and distribution for mouse (M) hyperplasia (NTP, 2008).

Figure D-7 Model outputs and distribution for rat (M) liver ALT (12 months) (NTP, 2008).

Figure D-8 Model outputs and distribution for mouse (F) hyperplasia (NTP, 2008).

Figure D-9 Model outputs and distribution for mouse (F) liver chronic inflammation (2 years) (NTP, 2008).

Figure D-10 Model outputs and distribution for rat (F) liver chronic inflammation (2 years) (NTP, 2008).

Figure D-11 Model outputs and distribution for mouse (F) Decreased F1 postnatal growth (NTP, 1997).

Figure D-12 Model outputs and distribution for rat (M) decreased Hb at 22 days (NTP, 2008).

Figure D-13 Model outputs and distribution for rat (F) decreased Hb at 90 days (NTP, 2007f).

Figure D-14 Model outputs and distribution for rat (M) decreased Hb at 90 days (NTP, 2007f).

Figure D-15 Model outputs and distribution for rat (M) decreased Hb at 12 months (NTP, 2008).

Figure D-16 Model outputs and distribution for rat (F) decreased Hb at 23 days (NTP, 2007f).

Figure D-17 Model outputs and distribution for rat (M) decreased Hb at 23 days (NTP, 2007f).

Figure D-18 Model outputs and distribution for rat (F) small intestinal hyperplasia (Thompson et al., 2012c).

Figure D-19 Model outputs and distribution for mouse (F) crypt cell hyperplasia of the duodenum at 90 days (Thompson et al., 2011b)

### D.6.2 Cancer Model Outputs

Figure D-20 Model outputs and distribution for adenomas or carcinomas in the female mouse small intestine (external dose modeling, BMR of 10% ER) (NTP, 2008).

Figure D-21 Model outputs and distribution for adenomas or carcinomas in the male mouse small intestine (external dose modeling, BMR of 10% ER) (NTP, 2008).

Figure D-22 Model outputs and distribution for adenomas or carcinomas in the female mouse small intestine (internal dose modeling, BMR of 1% ER) (NTP, 2008).

Figure D-23 Model outputs and distribution for adenomas or carcinomas in the male mouse small intestine (internal dose modeling, BMR of 1% ER) (NTP, 2008).

Figure D-24 Model outputs and distribution for adenomas or carcinomas in the female mouse small intestine (external dose modeling, BMR of 1% ER) (NTP, 2008).

Figure D-25 Model outputs and distribution for adenomas or carcinomas in the male mouse small intestine (external dose modeling, BMR of 1% ER) (NTP, 2008).

## D.7 UNCERTAINTY FACTORS

Consistent with EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002), a series of five UFs were applied to the POD developed for each endpoint/study, specifically addressing the following areas of uncertainty: interspecies uncertainty (UF_A_) to account for animal-to-human extrapolation, and consisting of equal parts representing pharmacokinetic and pharmacodynamic differences; intraspecies uncertainty (UF_H_) to account for variation in susceptibility across the human population, and the possibility that the available data may not be representative of individuals who are most susceptible to the effect; LOAEL-to-NOAEL uncertainty (UF_L_) to infer an exposure level where effects are not expected when a POD is based on a lowest-observed-adverse-effect level (LOAEL); subchronic-to-chronic uncertainty (UF_S_) to account for the uncertainty in using subchronic studies to make inferences about lifetime exposure, and to consider whether lifetime exposure would have effects at lower levels (e.g., for studies other than subchronic studies); and database uncertainty (UF_D_) to account for database deficiencies if an incomplete database raises concern that further studies might identify a more sensitive effect, organ system, or life stage.

Table D-23 below outlines uncertainty factor rationales for each individual endpoint.

Table D-23 Overview of uncertainty factor application for oral studies

Endpoint and reference | Dur. | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite
Mouse (F) hyperplasia NTP (2007f) | 90 d | LOAEL | 3 | 3 | 10 (LOAEL used) | 3 (subchronic data) | 1 | 300
Mouse (F) Crypt cell hyperplasia Thompson et al. (2011b) | 90 d | NOAEL | 3 | 3 | 1 (NOAEL used) | 3 (subchronic data) | 1 | 30
Mouse (F) Villous cytoplasmic vacuolization Thompson et al. (2011b) | 90 d | NOAEL | 3 | 3 | 1 (NOAEL used) | 3 (subchronic data) | 1 | 30
Rat (M) liver ALT NTP (2008) | 12 mo | BMDL_1RD_ | 3 | 3 | 1 (BMDL used) | 1 (chronic data) | 1 | 10
Rat (M) liver ALT NTP (2008) | 3 mo | NOAEL | 3 | 3 | 1 (NOAEL used) | 3 (subchronic data) | 1 | 30
Rat (M) liver ALT NTP (2007f) | 90 d | LOAEL | 3 | 3 | 10 (LOAEL used) | 3 (subchronic data) | 1 | 300
Rat (F) liver ALT NTP (2007f) | 90 d | LOAEL | 3 | 3 | 10 (LOAEL used) | 3 (subchronic data) | 1 | 300
Rat (F) liver chronic inflammation NTP (2008) | 2 yr | LOAEL | 3 | 3 | 10 (LOAEL used) | 1 (chronic data) | 1 | 100
Mouse (F) liver chronic inflammation NTP (2008) | 2 yr | BMDL_10%ER_ | 3 | 3 | 1 (BMDL used) | 1 (chronic data) | 1 | 10
Rat (F) liver fatty change NTP (2008) | 2 yr | NOAEL | 3 | 3 | 1 (NOAEL used) | 1 (chronic data) | 1 | 10
Mouse (F) Decreased F1 postnatal growth NTP (1997) | Multigen | NOAEL | 3 | 3 | 1 (NOAEL used) | 1 (critical window) | 1 | 10
Rat (M) Hgb NTP (2008) | 22 d | BMDL_1SD_ | 3 | 3 | 1 (BMDL used) | 1 (not extrapolating to chronic) | 1 | 10
Rat (M) Hgb NTP (2008) | 3 mo | NOAEL | 3 | 3 | 1 (NOAEL used) | 1 (not extrapolating to chronic) | 1 | 10
Rat (M) Hgb NTP (2008) | 12 mo | NOAEL | 3 | 3 | 1 (NOAEL used) | 1 (chronic data) | 1 | 10
Rat (M) Hgb NTP (2007f) | 90 d | BMDL_1SD_ | 3 | 3 | 1 (BMDL used) | 1 (not extrapolating to chronic) | 1 | 10
Rat (M) Hgb NTP (2007f) | 23 d | LOAEL | 3 | 3 | 10 (LOAEL used) | 1 (not extrapolating to chronic) | 1 | 100
Rat (F) Hgb NTP (2007f) | 90 d | NOAEL | 3 | 3 | 1 (NOAEL used) | 1 (not extrapolating to chronic) | 1 | 10
Rat (F) Hgb NTP (2007f) | 23 d | LOAEL | 3 | 3 | 10 (LOAEL used) | 1 (not extrapolating to chronic) | 1 | 100

For all studies: UF_A_ = 3 (animal study used with PK model; residual PD uncertainty); UF_H_ = 3 (lower 99% PK results used; 3 retained for PD variability); UF_D_ =1 (strong database).

Note: An uncertainty factor of 3 indicates half an order of magnitude (10^1/2^ = 3.16, rounded to 3). For simplicity, 10^1/2^ is used when multiplying values of 3 together, and 3.0 is used when solely multiplying it by 1 or 10.

## D.8 SELECTED BMD LOGFILE OUTPUTS

In response to comments by external peer reviewers, BMD logfile outputs for selected endpoints are presented here. All BMD logfiles are available in (U.S. EPA, 2021a). Logfiles have been edited from the originals for 508 compliances. Note that BMDS automatic determination of “recommended” or “questionable” models are only suggestions. EPA evaluates model fit using the steps outlined in Appendix D.1.1 and D.2.1.

### D.8.1 Analysis Name: Male mouse hyperplasia (NTP, 2008)

Data

Dose | Num animals | Incidence
0 | 39 | 0
0.45 | 43 | 11
0.914 | 45 | 18
2.4 | 48 | 42

#### Frequentist Multistage Restricted

User Input

Info
Model | Frequentist multistage degree 1 v1.1
Dataset name | DEH_mice_M
User notes | Highest dose dropped

Model options
Risk Type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 4

Model Results

Benchmark dose
BMD | 0.148221016
BMDL | 0.120812899
BMDU | 0.183855782
AIC | 149.9503258
p-value | 0.532809952
D.O.F. | 3
Chi^2^ | 2.195628407
Slope Factor | 0.827726182

Model parameters
# of parameters | 2
Variable | Estimate
g | Bounded
b1 | 0.710833854

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 1.523E–08 | 5.93969E–07 | 0 | 39 | −0.000771
0.45 | 0.27376037 | 11.77169591 | 11 | 43 | −0.263929
0.914 | 0.477798713 | 21.50094208 | 18 | 45 | −1.04481
2.4 | 0.818409525 | 39.28365721 | 42 | 48 | 1.0170261

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −72.82170084 | 4 | - | - | NA
Fitted Model | −73.97516289 | 1 | 2.30692411 | 3 | 0.5111957
Reduced Model | −118.1706207 | 1 | 90.6978396 | 3 | <0.0001

Figure D-26 Frequentist multistage degree 1 model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation | BMDS recommendation notes
Dichotomous Hill | Restricted | Extra risk | 0.281488 | 0.165474 | 0.3936159 | 0.3208198 | 151.9176474 | Viable – Alternate
Gamma | Restricted | Extra risk | 0.234037 | 0.127694 | 0.3619784 | 0.6004525 | 150.6612164 | Viable – Alternate | BMDL 3x lower than lowest non-zero dose
Log-Logistic | Restricted | Extra risk | 0.281488 | 0.165474 | 0.3936162 | 0.131581 | 153.9176479 | Viable – Alternate
Multistage Degree 3 | Restricted | Extra risk | 0.185262 | 0.132663 | 0.3092362 | 0.5746625 | 151.9545148 | Viable – Alternate | BMDL 3x lower than lowest non-zero dose
Multistage Degree 2 | Restricted | Extra risk | 0.199617 | 0.131348 | 0.3148831 | 0.7660982 | 150.1708362 | Viable – Alternate | BMDL 3x lower than lowest non-zero dose
Multistage Degree 1 * | Restricted | Extra risk | 0.148221 | 0.120813 | 0.1838558 | 0.53281 | 149.9503258 | Viable – Recommended; Notes:; BMD 3x lower than lowest non-zero dose; BMDL 3x lower than lowest non-zero dose | Lowest AIC. BMDL estimates for models not excluded (based on goodness-of-fit p-values less than 0.1, or high scaled residuals) are sufficiently close.
Weibull | Restricted | Extra risk | 0.225969 | 0.128897 | 0.3451728 | 0.357164 | 152.484914 | Viable – Alternate | BMDL 3x lower than lowest non-zero dose
Logistic | Unrestricted | Extra risk | 0.425163 | 0.34482 | 0.5237088 | 0.0527763 | 158.9167365 | Questionable | Goodness of fit p-value < 0.1
Log-Probit | Unrestricted | Extra risk | 0.292474 | 0.17905 | 0.3977474 | 0.1374657 | 153.8505115 | Viable – Alternate
Probit | Unrestricted | Extra risk | 0.407146 | 0.335036 | 0.4966644 | 0.0609178 | 158.2801013 | Questionable | Goodness of fit p-value < 0.1

* Selected model in bold; scaled residuals for selected model for doses 0, 0.45, 0.914, 2.4 were −7.70693979504052E–04, 0.808853623537301, −1.10949907747765, 0.623312250151613 [units], respectively.

### D.8.2 Analysis Name: Female mouse hyperplasia (NTP, 2008) (full dataset)

Data

Dose | N | Incidence
0 | 42 | 0
0.302 | 42 | 16
1.18 | 48 | 35
3.24 | 42 | 31
8.89 | 48 | 42

#### Frequentist Dichotomous Hill Restricted Option Set #1

User Input

Info
Model | Frequentist Dichotomous Hill v1.1
Dataset name | NTP_mouse_F_hyperplasia_full
User notes | [Add user notes here]

Model options
Risk type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated
Model data
Dependent variable | [Custom]
Independent variable | [Custom]
Total # of observations | 5

Model Results

Benchmark dose
BMD | 0.056091165
BMDL | 0.026809752
BMDU | 0.224515276
AIC | 204.0800247
p-value | 0.413229077
D.O.F. | 2
Chi2 | 1.767506346

Model parameters
# of parameters | 4
Variable | Estimate
g | Bounded
v | 0.874944835
a | 1.114120258
b | 1.097530966

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 1.523E–08 | 6.39659E–07 | 0 | 42 | −0.0008
0.302 | 0.393873766 | 16.54269819 | 16 | 42 | −0.171385
1.18 | 0.686939741 | 32.97310754 | 35 | 48 | 0.6308655
3.24 | 0.802462912 | 33.70344229 | 31 | 42 | −1.047745
8.89 | 0.849598887 | 40.78074657 | 42 | 48 | 0.4923125

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −98.18295952 | 5 | - | - | NA
Fitted Model | −99.04001234 | 3 | 1.71410565 | 2 | 0.4244111
Reduced Model | −152.3526517 | 1 | 108.339384 | 4 | <0.0001

Figure D-27 Frequentist Dichotomous Hill Model with BMR of 10% Extra Risk for the BMD and 0.95 LCL for the BMDL

#### Frequentist Log-Logistic Restricted Option Set #1

User Input

Info
Model | Frequentist Log-Logistic v1.1
Dataset Name | NTP_mouse_F_hyperplasia_full
User notes | [Add user notes here]

Model options
Risk type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | [Custom]
Independent variable | [Custom]
Total # of observations | 5

Model Results

Benchmark dose
BMD | 0.072187131
BMDL | 0.052983093
BMDU | 0.100906352
AIC | 205.072852
p-value | 0.11446507
D.O.F. | 4
Chi2 | 7.438209323

Model parameters
# of parameters | 3
Variable | Estimate
g | Bounded
a | 0.431268917
b | Bounded

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 1.523E–08 | 6.39659E–07 | 0 | 42 | −0.0008
0.302 | 0.317332175 | 13.32795137 | 16 | 42 | 0.8858454
1.18 | 0.64492005 | 30.95616239 | 35 | 48 | 1.2197114
3.24 | 0.832972515 | 34.98484562 | 31 | 42 | −1.648457
8.89 | 0.93189668 | 44.73104063 | 42 | 48 | −1.56473

Analysis of Deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −98.18295952 | 5 | – | – | NA
Fitted Model | −101.536426 | 1 | 6.70693301 | 4 | 0.15221
Reduced Model | −152.3526517 | 1 | 108.339384 | 4 | <0.0001

Figure D-28 Frequentist Log-Logistic Model with BMR of 10% Extra Risk for the BMD and 0.95 LCL for the BMDL.

#### Frequentist Log-Probit Unrestricted Option Set #1

User Input

Info
Model | Frequentist Log-Probit v1.1
Dataset name | NTP_mouse_F_hyperplasia_full
User notes | [Add user notes here]

Model options
Risk type | Extra Risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | [Custom]
Independent variable | [Custom]
Total # of observations | 5

Model Results

Benchmark dose
BMD | 0.019881459
BMDL | 0.001989959
BMDU | 0.06430057
AIC | 204.7996679
p-value | 0.304286067
D.O.F. | 2
Chi2 | 2.37957402

Model parameters
# of parameters | 3
Variable | Estimate
g | 1.63869E–08
a | 0.299257175
b | 0.403476716

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 1.63869E–08 | 6.88248E–07 | 0 | 42 | −0.00083
0.302 | 0.427070713 | 17.93696995 | 16 | 42 | −0.604224
1.18 | 0.642831794 | 30.85592611 | 35 | 48 | 1.2483081
3.24 | 0.780408522 | 32.77715791 | 31 | 42 | −0.662419
8.89 | 0.881163751 | 42.29586004 | 42 | 48 | −0.131966

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −98.18295952 | 5 | - | - | NA
Fitted Model | −99.39983394 | 3 | 2.43374884 | 2 | 0.2961544
Reduced Model | −152.3526517 | 1 | 108.339384 | 4 | <0.0001

Figure D-29 Frequentist Log-Probit Model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation | BMDS recommendation notes
Dichotomous Hill | Restricted | Extra risk | 0.056091 | 0.02681 | 0.2245153 | 0.4132291 | 204.0800247 | Questionable | BMD 3x lower than lowest non-zero dose BMDL 10x lower than lowest non-zero dose
Gamma | Restricted | Extra risk | 0.30249 | 0.22881 | 0.4169903 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Log-Logistic | Restricted | Extra risk | 0.072187 | 0.052983 | 0.1009064 | 0.1144651 | 205.072852 | Viable – Recommended | Lowest AIC BMD 3x lower than lowest non-zero dose BMDL 3x lower than lowest non-zero dose
Multistage Degree 4 | Restricted | Extra risk | 0.30249 | 0.22881 | 0.4163446 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Multistage Degree 3 | Restricted | Extra risk | 0.302492 | 0.228807 | 0.4163416 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Multistage Degree 2 | Restricted | Extra risk | 0.30249 | 0.228809 | 0.4163386 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Multistage Degree 1 | Restricted | Extra risk | 0.302506 | 0.22881 | 0.416339 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Weibull | Restricted | Extra risk | 0.30249 | 0.22881 | 0.4163057 | <0.0001 | 241.1044934 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Logistic | Unrestricted | Extra risk | 0.727109 | 0.578508 | 0.9315833 | <0.0001 | 255.4945352 | Questionable | Goodness of fit p-value < 0.1 \|Residual at control\| > 2
Log-Probit | Unrestricted | Extra risk | 0.019881 | 0.00199 | 0.0643006 | 0.3042861 | 204.7996679 | Questionable | BMD/BMDL ratio > 3 BMD 10x lower than lowest non-zero dose BMDL 10x lower than lowest non-zero dose
Probit | Unrestricted | Extra risk | 0.803221 | 0.662194 | 1.0008101 | <0.0001 | 257.1209428 | Questionable | Goodness of fit p-value < 0.1 \|Residual for Dose Group Near BMD\| > 2 \|Residual at control\| > 2

### D.8.3 Analysis Name: Small intestine tumors vs. external dose) (male mice, 10% BMR) (NTP, 2008)

Data

Dose | Num animals | Incidence
0 | 50 | 1
0.45 | 49 | 3
0.914 | 49 | 2
2.4 | 50 | 7
5.7 | 50 | 20

#### Frequentist Multistage Restricted

User Input

Info
Model | Frequentist Multistage degree 1 v1.1
Dataset name | GI_tumors_male_mice
User notes | doses in mg/kg-d

Model options
Risk type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model Data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Model Results

Benchmark dose
BMD | 1.439517367
BMDL | 1.05331908
BMDU | 2.105566675
AIC | 163.2611412
p-value | 0.535925969
D.O.F. | 3
Chi^2^ | 2.179861218
Slope Factor | 0.094937994

Model parameters
# of parameters | 2
Variable | Estimate
g | 0.015871837
b1 | 0.07319155

Goodness of Fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.015871837 | 0.793591838 | 1 | 50 | 0.2335621
0.45 | 0.047757301 | 2.340107737 | 3 | 49 | 0.4420601
0.914 | 0.079553333 | 3.898113332 | 2 | 49 | −1.002064
2.4 | 0.17441154 | 8.720577001 | 7 | 50 | −0.641239
5.7 | 0.351563356 | 17.57816778 | 20 | 50 | 0.7173374

Analysis of Deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −78.44252975 | 5 | - | - | NA
Fitted Model | −79.63057059 | 2 | 2.37608168 | 3 | 0.4981025
Reduced Model | −97.25840347 | 1 | 37.6317475 | 4 | <0.0001

Figure D-30 Frequentist Multistage Degree 1 Model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-Value | AIC | BMDS recommendation | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 2.177821 | 1.165275 | 3.5826436 | 0.3543431 | 165.7318655 | Viable – Alternate
Multistage Degree 2 | Restricted | Extra risk | 2.154726 | 1.162427 | 3.1962728 | 0.6323371 | 163.7603621 | Viable – Alternate
Multistage Degree 1 * | Restricted | Extra risk | 1.439517 | 1.053319 | 2.1055667 | 0.535926 | 163.2611412 | Viable – Recommended | Lowest AIC. All parameter estimates positive in all models.

* Selected model in bold; scaled residuals for selected model for doses 0, 0.45, 0.914, 2.4, 5.7 were −0.224809820450452, 0.718917352150516, −0.55190626916719, 8.24573517804963E–02, −5.70553325093666E–03 [units], respectively.

### D.8.4 Analysis Name: Small intestine tumors vs. external dose (female mice, 10% BMR) (NTP, 2008)

Data

Dose | Num animals | Incidence
0 | 49 | 1
0.302 | 50 | 1
1.18 | 49 | 4
3.24 | 50 | 17
8.89 | 49 | 22

#### Frequentist Multistage Restricted

User Input

Info
Model | Frequentist Multistage degree 1 v1.1
Dataset name | GI_tumors_female_mice
User notes | dose in mg/kg-d

Model options
Risk type | Extra Risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Model Results

Benchmark dose
BMD | 1.341093574
BMDL | 1.034024507
BMDU | 1.811678864
AIC | 187.1308173
p-value | 0.2143268
D.O.F. | 3
Chi^2^ | 4.477269267
Slope factor | 0.096709507

Model parameters
# of parameters | 2
Variable | Estimate
g | 0.01501814
b1 | 0.078563127

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.01501814 | 0.735888879 | 1 | 49 | 0.3102176
0.302 | 0.038112827 | 1.905641355 | 1 | 50 | −0.668919
1.18 | 0.10222567 | 5.009057819 | 4 | 49 | −0.475833
3.24 | 0.236373579 | 11.81867895 | 17 | 50 | 1.7247079
8.89 | 0.51010209 | 24.99500242 | 22 | 49 | −0.85589

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −89.39814603 | 5 | – | – | NA
Fitted Model | −91.56540867 | 2 | 4.33452528 | 3 | 0.2275337
Reduced Model | −117.2490322 | 1 | 55.7017724 | 4 | <0.0001

Figure D-31 Frequentist Multistage Degree 1 Model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation | BMDS Recommendation notes
Multistage Degree 4 | Restricted | Extra risk | 1.341094 | 1.034023 | 1.9319014 | 0.2143276 | 187.1308173 | Viable – Alternate
Multistage Degree 3 | Restricted | Extra risk | 1.341094 | 1.034033 | 1.9318743 | 0.2143276 | 187.1308173 | Viable – Recommended | Lowest AIC
Multistage Degree 2 | Restricted | Extra risk | 1.341094 | 1.034031 | 1.9318762 | 0.2143275 | 187.1308173 | Viable – Alternate
Multistage Degree 1 | Restricted | Extra risk | 1.341094 | 1.034025 | 1.8116789 | 0.2143268 | 187.1308173 | Viable – Alternate | All (equivalent) models provide adequate fit.

* Selected model in bold; scaled residuals for selected model for doses 0, 0.302, 1.18, 3.24, 8.89 were 0.310196196987839, −0.668927976883956, −0.475839144011481, 1.72470279264253, −0.855892469138338 [units], respectively.

### D.8.5 Analysis Name: Small intestine tumors vs. internal dose (male mice, 1% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model Restriction | Restricted
Dataset Name | GI_tumors_male_mice_int
User notes | Doses in mg/kg-d escaping

Model options
Risk type | Extra risk
BMR | 0.01
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark dose
BMD | 0.028758741
BMDL | 0.020834496
BMDU | 0.042610104
AIC | 162.2271486
p-value | 0.732559515
D.O.F. | 3
Chi^2^ | 1.285582307
Slope factor | 0.479973222

Model parameters
# of parameters | 2
Variable | Estimate | Std error | Lower conf | Upper conf
g | 0.019222019 | 5.00E-02 | −0.0788696 | 0.11731361
b1 | 0.349470654 | 0.591196137 | −0.8092525 | 1.5081938

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.019222019 | 0.961100945 | 1 | 50 | 0.0400654
0.07 | 0.04292365 | 2.103258834 | 3 | 49 | 0.6320442
0.149 | 0.068985374 | 3.380283311 | 2 | 49 | −0.778061
0.443 | 0.159891866 | 7.994593277 | 7 | 50 | −0.383778
1.29 | 0.375139159 | 18.75695794 | 20 | 50 | 0.3630889

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −78.44252974 | 5 | – | – | NA
Fitted Model | −79.11357432 | 2 | 1.34208916 | 3 | 0.7191637
Reduced Model | −97.25840347 | 1 | 37.6317475 | 4 | <0.0001

Figure D-32 Frequentist Multistage Degree 1 Model with BMR of 1% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-Value | AIC | BMDS recommendation | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.043488 | 0.02143 | 0.2735562 | 0.3477733 | 165.7416345 | Viable – Alternate
Multistage Degree 2 | Restricted | Extra risk | 0.044774 | 0.02143 | 0.2136004 | 0.6423346 | 163.7419624 | Viable – Alternate
Multistage Degree 1 ^*^ | Restricted | Extra risk | 0.028759 | 0.020834 | 0.0426101 | 0.7325595 | 162.2271486 | Viable – Recommended | Lowest AIC. All parameter estimates positive in all models.

* Selected model in bold; scaled residuals for selected model for doses 0, 0.07, 0.149, 0.443, 1.29 were −0.232410709733234, 0.715554636798668, −0.555514406965763, 8.31539929558845E-02, −4.63344353552081E-03 [units], respectively.

### D.8.6 Analysis Name: Small intestine tumors vs. internal dose (female mice, 1% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model restriction | Restricted
Dataset name | GI_tumors_female_mice_int
User notes | dose in mg/kg-d

Model options
Risk type | Extra risk
BMR | 0.01
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark dose
BMD | 0.030505528
BMDL | 0.023207702
BMDU | 0.042239975
AIC | 189.7814534
p-value | 0.055611109
D.O.F. | 3
Chi^2^ | 7.577062139
Slope factor | 0.430891433

Model parameters
# of parameters | 2
Variable | Estimate | Std error | Lower conf | Upper conf
g | 0.021011918 | 0.051572053 | −0.0800675 | 0.12209129
b1 | 0.329459388 | 0.331665171 | −0.3205924 | 0.97951118

Goodness of Fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.021011918 | 1.029583989 | 1 | 49 | −0.029467
0.0463 | 0.035832052 | 1.791602617 | 1 | 50 | −0.602296
0.197 | 0.08253359 | 4.044145896 | 4 | 49 | −0.022918
0.636 | 0.206079526 | 10.30397629 | 17 | 50 | 2.3411328
2.31 | 0.542641164 | 26.58941703 | 22 | 49 | −1.316057

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −89.39814602 | 5 | – | – | NA
Fitted Model | −92.89072669 | 2 | 6.98516134 | 3 | 0.0723722
Reduced Model | −117.2490322 | 1 | 55.7017724 | 4 | <0.0001

Figure D-33 Multistage Degree 1 Model with BMR of 1% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.030506 | 0.023208 | 0.0434931 | 0.0556111 | 189.7814534 | Bounded parameters
Multistage Degree 2 | Restricted | Extra risk | 0.030506 | 0.023208 | 0.0434939 | 0.0556111 | 189.7814534 | Bounded parameter
Multistage Degree 1 | Restricted | Extra risk | 0.030506 | 0.023208 | 0.04224 | 0.0556111 | 189.7814534 | No bounded parameters. Goodness-of-fit >0.05

### D.8.7 Analysis Name: Small intestine tumors vs. external dose (male mice,1% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model restriction | Restricted
Dataset name | GI_tumors_male_mice
User notes | Doses in mg/kg-d

Model options
Risk type | Extra risk
BMR | 0.01
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark Dose
BMD | 0.137313634
BMDL | 0.100480594
BMDU | 0.200869587
AIC | 163.2611411
p-value | 0.53591901
D.O.F. | 3
Chi^2^ | 2.179896356
Slope factor | 0.099521705

Model Parameters
# of parameters | 2
Variable | Estimate
g | 0.015869176
b1 | 0.073192569

Goodness of Fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.015869176 | 0.793458788 | 1 | 50 | 0.233732
0.45 | 0.047755163 | 2.340002973 | 3 | 49 | 0.4421396
0.914 | 0.079551702 | 3.898033395 | 2 | 49 | −1.002031
2.4 | 0.174411327 | 8.720566357 | 7 | 50 | −0.641235
5.7 | 0.351565369 | 17.57826846 | 20 | 50 | 0.7173066

Analysis of Deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −78.44252974 | 5 | - | - | NA
Fitted Model | −79.63057057 | 2 | 2.37608166 | 3 | 0.4981025
Reduced Model | −97.25840347 | 1 | 37.6317475 | 4 | <0.0001

Figure D-34 Frequentist Multistage Degree 1 Model with BMR of 1% extra risk for the BMD and 0.96 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.251299 | 0.111157 | 1.6335173 | 0.3543437 | 165.7318655 | Viable – Alternate
Multistage Degree 2 | Restricted | Extra risk | 0.329294 | 0.11089 | 0.9871797 | 0.6323371 | 163.7603621 | Viable – Alternate
Multistage Degree 1 * | Restricted | Extra risk | 0.137314 | 0.100481 | 0.2008696 | 0.535919 | 163.2611411 | Viable – Recommended | Lowest AIC All models had positive parameters, p-value > 0.05

* Selected model in bold; scaled residuals for selected model for doses 0, 0.45, 0.914, 2.4, 5.7 were −0.192673987799691, 0.679616818391591, −0.58713690952347, 0.118179583824583, −1.19164232770633E-02 [units], respectively.

### D.8.8 Analysis Name: Small intestine tumors vs. external dose (female mice, 1% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model restriction | Restricted
Dataset name | GI_tumors_female_mice
User notes | dose in mg/kg-d

Model options
Risk type | Extra risk
BMR | 0.01
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark dose
BMD | 0.127926762
BMDL | 0.098625682
BMDU | 0.172806756
AIC | 187.1308173
p-value | 0.214327554
D.O.F. | 3
Chi^2^ | 4.477260893
Slope factor | 0.101393468

Model parameters
# of parameters | 2
Variable | Estimate
g | 0.015018454
b1 | 0.078563138

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.015018454 | 0.735904256 | 1 | 49 | 0.3101964
0.302 | 0.038113137 | 1.905656826 | 1 | 50 | −0.668928
1.18 | 0.102225967 | 5.009072364 | 4 | 49 | −0.475839
3.24 | 0.236373848 | 11.81869238 | 17 | 50 | 1.7247028
8.89 | 0.510102291 | 24.99501224 | 22 | 49 | −0.855893

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −89.39814602 | 5 | – | – | NA
Fitted Model | −91.56540867 | 2 | 4.3345253 | 3 | 0.2275337
Reduced Model | −117.2490322 | 1 | 55.7017724 | 4 | <0.0001

Figure D-35 Frequentist Multistage Degree 1 Model with BMR of 1% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.127927 | 0.098626 | 0.200606 | 0.2143276 | 187.1308173
Multistage Degree 2 | Restricted | Extra risk | 0.127927 | 0.098625 | 0.2006104 | 0.2143275 | 187.1308173
Multistage Degree 1 * | Restricted | Extra risk | 0.127927 | 0.098626 | 0.1728068 | 0.2143276 | 187.1308173 | All models are equivalent, and have adequate p-value (>0.05) and positive parameters

* Selected model in bold; scaled residuals for selected model for doses 0, 0.302, 1.18, 3.24, 8.89 were 0.310196293047968, −0.668927944519767, −0.475839135967064, 1.72470277296316, −0.855892511784021 [units], respectively.

### D.8.9 Analysis Name: Small intestine tumors vs. internal dose (male mice, 10% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model restriction | Restricted
Dataset name | GI_tumors_male_mice_int
User notes | doses in mg/kg-d escaping

Model options
Risk type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark dose
BMD | 0.301486042
BMDL | 0.218413884
BMDU | 0.446693103
AIC | 162.2271486
p-value | 0.732559515
D.O.F. | 3
Chi^2^ | 0.019222019
Slope factor | 0.349470654

Model parameters
# of parameters | 2
Variable | Estimate | Std error | Lower conf | Upper conf
g | 0.019222019 | 5.00E-02 | −0.0788696 | 0.11731361
b1 | 0.349470654 | 0.591196137 | −0.8092525 | 1.5081938

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.019222019 | 0.961100945 | 1 | 50 | 0.0400654
0.07 | 0.04292365 | 2.103258834 | 3 | 49 | 0.6320442
0.149 | 0.068985374 | 3.380283311 | 2 | 49 | −0.778061
0.443 | 0.159891866 | 7.994593277 | 7 | 50 | −0.383778
1.29 | 0.375139159 | 18.75695794 | 20 | 50 | 0.3630889

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −78.44252974 | 5 | – | – | NA
Fitted Model | −79.11357432 | 2 | 1.34208916 | 3 | 0.7191637
Reduced Model | −97.25840347 | 1 | 37.6317475 | 4 | <0.0001

Figure D-36 Frequentist Multistage Degree 1 Model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.394427512 | 0.224660833 | 0.75463983 | 0.347773263 | 165.7416345 | Viable – Alternate
Multistage Degree 2 | Restricted | Extra risk | 0.394452808 | 0.224656079 | 0.691609485 | 0.642334638 | 163.7419624 | Viable – Alternate
Multistage Degree 1 * | Restricted | Extra risk | 0.301486042 | 0.218413884 | 0.446693103 | 0.732559515 | 162.2271486 | Viable – Recommended | Lowest AIC. All parameter estimates positive in all models.

* Selected model in bold; scaled residuals for selected model for doses 0, 0.07, 0.149, 0.443, 1.29 were −0.232410709733234, 0.715554636798668, −0.555514406965763, 8.31539929558845E-02, −4.63344353552081E-03 [units], respectively.

### D.8.10 Analysis Name: Small intestine tumors vs. internal dose (female mice, 10% BMR) (NTP, 2008)

Info
Model | Multistage degree 1
Model restriction | Restricted
Dataset name | GI_tumors_female_mice_int
User notes | dose in mg/kg-d

Model options
Risk type | Extra risk
BMR | 0.1
Confidence level | 0.95
Background | Estimated

Model data
Dependent variable | Dose
Independent variable | Incidence
Total # of observations | 5

Benchmark dose
BMD | 0.31979822
BMDL | 0.243291893
BMDU | 0.442810239
AIC | 189.7814534
p-value | 0.055611109
D.O.F. | 3
Chi^2^ | 7.577062139
Slope Factor | 0.411028904

Model parameters
# of Parameters | 2
Variable | Estimate | Std error | Lower conf | Upper conf
g | 0.021011918 | 0.051572053 | −0.0800675 | 0.12209129
b1 | 0.329459388 | 0.331665171 | −0.3205924 | 0.97951118

Goodness of fit
Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.021011918 | 1.029583989 | 1 | 49 | −0.029467
0.0463 | 0.035832052 | 1.791602617 | 1 | 50 | −0.602296
0.197 | 0.08253359 | 4.044145896 | 4 | 49 | −0.022918
0.636 | 0.206079526 | 10.30397629 | 17 | 50 | 2.3411328
2.31 | 0.542641164 | 26.58941703 | 22 | 49 | −1.316057

Analysis of deviance
Model | Log likelihood | # of parameters | Deviance | Test d.f. | P-value
Full Model | −89.39814602 | 5 | – | – | NA
Fitted Model | −92.89072669 | 2 | 6.98516134 | 3 | 0.0723722
Reduced Model | −117.2490322 | 1 | 55.7017724 | 4 | <0.0001

Figure D-37 Multistage Degree 1 Model with BMR of 10% extra risk for the BMD and 0.95 LCL for the BMDL.

Summary of Results

Model | Restriction | Risk type | BMD | BMDL | BMDU | P-value | AIC | BMDS recommendation notes
Multistage Degree 3 | Restricted | Extra risk | 0.31979822 | 0.243292795 | 0.445346696 | 0.055611108 | 189.7814534 | Bounded parameters
Multistage Degree 2 | Restricted | Extra risk | 0.31979822 | 0.243292795 | 0.445346696 | 0.055611109 | 189.7814534 | Bounded parameter
Multistage Degree 1 | Restricted | Extra risk | 0.31979822 | 0.243291893 | 0.442810239 | 0.055611109 | 189.7814534 | No bounded parameters. Goodness-of-fit >0.05

* Selected model in bold; scaled residuals for selected model for doses 0, 0.0463, 0.197, 0.636, 2.31 were −0.029467082, −0.602296074, −0.022918271, 2.341132837, −1.316056633 [units], respectively.

7 For the χ^2^ goodness-of-fit test and a p-value of α, the critical value is the 1 - α percentile of the χ^2^ distribution at the appropriate degrees of freedom. Models are rejected if there are large values of χ^2^ corresponding to p-values less than 0.1, the limiting probability of a Type I error (false positive) selected for this purpose.

8 Scaled residuals reported by BMDS for dichotomous responses are defined as (Observed - Expected)/SE, where "Expected" is the predicted number of responders and SE equals the estimated standard error of that predicted number. For dichotomous models, the estimated standard error is equal to √[n x p x (1 - p)], where n is the sample size and p is the model-predicted probability of response. Model fit is considered questionable if the scaled residual value for any dose group, particularly the control or low dose group, is greater than 2 or less than -2.

9 The 1/10,000 risk level was arbitrarily chosen for this exercise, primarily to provide an illustration using relatively small values that were consistent in magnitude. Values provided here can be scaled-up to different risk levels. For example, at 1/million risk using OSF of 0.5 per mg/kg-d, there would be a 450/1,000,000 increased cancer risk at the RfD.

10 ADAF calculation: 10 × 0.1 × 2/70 + 3 × 0.1 × 14/70 + 1 × 0.1 × 54/70 = 0.166 (see Section 4.3.4).