# APPENDIX C INFORMATION IN SUPPORT OF HAZARD IDENTIFICATION AND DOSE-RESPONSE ANALYSIS

## C.1 PHARMACOKINETICS

### C.1.1 Absorption

Water soluble Cr(VI) compounds are rapidly absorbed into cells and tissues in the body via phosphate and sulfate anion transport due to the structural similarity of the tetrahedral configuration of the chromate (CrO_4_^2−^) or dichromate (Cr_2_O_7_^2−^) anion to that of phosphate (HPO_4_^2−^) and sulfate (SO_4_^2−^) anions (Wetterhahn et al., 1989; Alexander and Aaseth, 1995), while Cr(III) compounds are absorbed slowly by passive diffusion (Eastmond et al., 2008). In the gastrointestinal (GI) tract following oral ingestion, systemic uptake of Cr(VI) competes with the rapid extracellular reduction to Cr(III) by gastric juices (Proctor et al., 2012; De Flora et al., 1997). Studies listed in Appendix C.1.6 that administered Cr(VI) and Cr(III) to different treatment groups have observed higher urinary, blood, and tissue chromium in the groups exposed to Cr(VI). This was also observed by separate NTP bioassays of Cr(VI) and Cr(III), which found the body burdens of rats and mice exposed to Cr(VI) in drinking water were significantly higher than those exposed to comparable levels of Cr(III) in feed (Collins et al., 2010). Figure C-1 illustrates the difference in chromium concentrations of selected systemic tissues between the Cr(VI) and Cr(III) studies. Despite the estimated daily dose of Cr(III) being threefold higher than that of Cr(VI), chromium tissue concentrations were over tenfold higher for the Cr(VI) group. Because Cr(VI) is more readily absorbed into the GI tract than Cr(III), this is also evidence that systemic absorption of Cr(VI) can occur in rodents following chronic oral exposure, despite reduction of Cr(VI) to Cr(III) by gastric juice (Collins et al., 2010).

Figure C-1 Comparison of mean tissue concentrations in mice (n = 3) following 182 days of either Cr(VI) or Cr(III) oral exposure.

Groups compared are the 516 mg/L SDD group and the 2000 mg/L sodium picolinate group. These correspond to approximately 10 mg/kg-day Cr(VI), and 30 mg/kg-day Cr(III) respectively (average over study period weeks 14–51). These are a subset of data from the NTP studies Collins et al. (2010). Data were collected after a 2-day washout period, and therefore concentrations are lower than what would have been measured during ongoing exposure.

Although fewer Cr(VI) pharmacokinetic studies are available for the inhalation route than for the oral route (see Appendix C.1.6), there is evidence that indicates inhaled Cr(VI) is absorbed systemically. The study in rats by Cohen et al. (1997) of inhaled soluble (potassium chromate) and insoluble (barium chromate) Cr(VI) observed absorption of both forms of Cr(VI). Elevated chromium in this study was observed in lung components and systemic tissues (kidney, liver, spleen), with higher levels in groups exposed to the soluble form of Cr(VI). Occupational studies in humans who may have been exposed primarily via inhalation have measured elevated chromium in multiple biomarkers such as red blood cells and urine (see Appendix C.1.6). O'Flaherty and Radike (1991) exposed rats to Cr(VI) or Cr(III) at concentrations of 200 μg/m^3^ via aerosol inhalation (6 hours/day) and detected elevated chromium in all measured tissues and excreta relative to controls (see Table C-6).

### C.1.2 Distribution

Upon systemic absorption, Cr(VI) circulates in plasma, where it is absorbed into red blood cells (RBCs), white blood cells, and other systemic tissues. Both the uptake and reduction of Cr(VI) by RBCs has been estimated to be rapid (Devoy et al., 2016). Uptake to RBCs is facilitated by nonspecific anion transport channels, including the band-3 anion exchanger protein, an anion carrier system of the red blood cell membrane (Ottenwälder et al., 1987; Ottenwaelder et al., 1988; Buttner and Beyersmann, 1985; Buttner et al., 1988). In humans, genetic polymorphisms in the band-3 protein have been shown to be associated with increased accumulation of Cr(VI) in red blood cells (Qu et al., 2008).

Because irreversible binding to hemoglobin occurs, and Cr(III) exhibits a lower rate of transport through cellular membranes than Cr(VI), Cr(III) remains trapped in RBCs over the remaining life of the cells. Supporting evidence is provided by the studies presented in Appendix C.1.6. This property has been exploited for diagnostic purposes whereby hexavalent radiolabeled chromium-51 has been used to label and determine the survival time of RBCs in humans (Gray and Sterling, 1950). Measured in vivo chromium concentration in plasma has been observed to rapidly decrease to background levels after exposure to Cr(VI) has ceased, while in vivo chromium concentration in RBCs decreases more gradually (as chromium-containing RBCs are replaced over time).

Because chromium in the system varies with uptake of Cr(III) [both from diet and from Cr(VI) reduction in the lumen], chromium concentration in RBCs may be normalized by concentration in plasma to evaluate systemic distribution. Although it is noted in Kirman et al. (2012) that the RBC:plasma ratios are generally equal to or less than 1 for low concentrations (and exceed 1 at 60–180 mg/L), evaluating the data for ratios greater than 1 to assess absorption and distribution may not be informative. For example, the RBC:plasma ratios are greater than 1 for some of the control groups for rats and mice analyzed in the NTP (2008) Cr(VI) study (see Tables C-2 and C-4). Instead, comparisons against control or Cr(III)-exposed groups are more appropriate. Despite the complications from the 48-hour washout period,^1^ a comparison of the NTP (2008) RBC:plasma ratio data for dosed animals against control groups and comparison with groups from the NTP (2007f) Cr(III) study can indicate systemic uptake of Cr(VI). A similar analysis using concentration data for plasma and RBCs in the Kirman et al. (2012) study could not be performed because concentrations are below the method detection limits for the control groups and low concentration groups. For that dataset, RBC:plasma ratios are not informative until Cr(VI) drinking water concentrations ≥20 mg/L in both species, and they cannot be compared with controls.

The RBC:plasma ratio analysis of NTP (2008) data are provided in Figure C-2 and Tables C-1 through C-4. Analysis of the NTP (2007f) Cr(III) data are not presented, but those data indicate RBC:plasma ratios <1 for all Cr(III) dietary exposure groups, with no dose-dependent increase. For rats exposed to Cr(VI) in drinking water, the RBC:plasma ratio increases by approximately 90%-225% above controls at 20 mg/L Cr(VI) drinking water concentration. For mice, the ratio increases by approximately 40%–100% above controls at 20 mg/L Cr(VI). Because this increase in relative RBC concentration was not observed in rodents exposed to Cr(III), Cr(VI) concentrations at or above 20 mg/L Cr(VI) in drinking water (equivalent to approximately^2^ 0.88 mg/kg-day in rats and 1.5 mg/kg-day in mice) likely result in systemic Cr(VI) absorption beyond the liver (where extensive reduction is expected to occur during the first-pass effect). More extensive systemic distribution likely occurs as dose increases, as more Cr(VI) could escape reduction in the stomach, small intestine, and liver.

Figure C-2 Ratio of RBC:plasma concentration as a function of Cr(VI) drinking water concentration (1 ppm = 1 mg/L) for male F334 rats and female B6C3F1 mice using data from NTP (2008).

Table C-1 Concentrations of chromium in erythrocytes and plasma (μg Cr/g) following ingestion of sodium dichromate dihydrate in drinking water (male F334 rats)

Cr(VI) concentrations | | 0 mg/L | 5 mg/L | 20 mg/L | 60 mg/L | 180 mg/L
Erythrocytes | Day | μg Cr/g | μg Cr/g | μg Cr/g | μg Cr/g | μg Cr/g
| 6 | 0.044 | 0.051 | 0.126 | 0.252 | 0.391
| 13 | 0.051 | 0.036 | 0.203 | 0.504 | 0.899
| 182 | 0.05 | 0.054 | 0.208 | 0.591 | 0.997
| 371 | 0.055 | 0.064 | 0.16 | 0.526 | 0.693
Plasma
| 6 | 0.052 | 0.068 | 0.079 | 0.087 | 0.109
| 13 | 0.054 | 0.048 | 0.079 | 0.103 | 0.146
| 182 | 0.063 | 0.064 | 0.081 | 0.099 | 0.146
| 371 | 0.054 | 0.062 | 0.071 | 0.11 | 0.146

Data from NTP (2008). Time-weighted average daily doses for each exposure group are not listed, since they vary with time over the lifespan of the rodent (and will be different at days 6, 13, 182, and 371).

Table C-2 Ratio of erythrocyte:plasma concentrations following ingestion of sodium dichromate dihydrate in drinking water (male F334 rats)

Cr(VI) | 0 mg/L | 5 mg/L | | 20 mg/L | | 60 mg/L | | 180 mg/L
Day | Ratio | Ratio | %↑↓ | Ratio | %↑↓ | Ratio | %↑↓ | Ratio | %↑↓
6 | 0.846 | 0.750 | −11.4 | 1.59 | 88.5 | 2.90 | 242 | 3.59 | 324
13 | 0.944 | 0.750 | −20.6 | 2.57 | 172 | 4.89 | 418 | 6.16 | 552
182 | 0.794 | 0.844 | 6.31 | 2.57 | 224 | 5.97 | 652 | 6.83 | 760
371 | 1.02 | 1.03 | 1.35 | 2.25 | 121 | 4.78 | 369 | 4.75 | 366
TWA: | 0.888 | 0.867 | −2.36 | 2.46 | 177 | 5.29 | 495 | 6.06 | 582

TWA = time-weighted average values.

For the chromium picolinate studies (NTP, 2007f), the RBC/plasma ratio did not increase as a function of dose for rats (data not shown).

Table C-3 Concentrations of chromium in erythrocytes and plasma (μg Cr/g) following ingestion of sodium dichromate dihydrate in drinking water (female B6C3F1 mice)

Cr(VI) concentrations | | 0 mg/L | 5 mg/L | 20 mg/L | 60 mg/L | 180 mg/L
Erythrocytes | Day | μg Cr/g | μg Cr/g | μg Cr/g | μg Cr/g | μg Cr/g
| 6 | 0.04 | 0.056 | 0.108 | 0.26 | 0.374
| 13 | 0.043 | 0.042 | 0.341 | 0.747 | 1.19
| 182 | 0.058 | 0.079 | 0.194 | 0.719 | 1.561
| 371 | 0.036 | 0.042 | 0.094 | 0.34 | 0.795
Plasma
| 6 | 0.064 | 0.075 | 0.111 | 0.15 | 0.213
| 13 | 0.034 | 0.038 | 0.133 | 0.204 | 0.311
| 182 | 0.051 | 0.07 | 0.116 | 0.167 | 0.253
| 371 | 0.065 | 0.086 | 0.118 | 0.15 | 0.209

Data from NTP (2008). Time-weighted average daily doses for each exposure group are not listed, since they vary with time over the lifespan of the rodent (and will be different at days 6, 13, 182, and 371).

Table C-4 Ratio of erythrocyte:plasma concentrations following ingestion of sodium dichromate dihydrate in drinking water (female B6C3F1 mice)

Cr(VI) | 0 mg/L | 5 mg/L | | 20 mg/L | | 60 mg/L | | 180 mg/L
Day | Ratio | Ratio | %↑↓ | Ratio | %↑↓ | Ratio | %↑↓ | Ratio | %↑↓
6 | 0.625 | 0.747 | 19.5 | 0.973 | 55.7 | 1.73 | 177 | 1.76 | 181
13 | 1.26 | 1.11 | −12.6 | 2.56 | 103 | 3.66 | 190 | 3.83 | 203
182 | 1.14 | 1.13 | −0.764 | 1.67 | 47.1 | 4.31 | 279 | 6.17 | 443
371 | 0.554 | 0.488 | −11.8 | 0.797 | 43.8 | 2.27 | 309 | 3.80 | 587
TWA: | 1.01 | 0.950 | −5.53 | 1.64 | 63.3 | 3.57 | 255 | 4.90 | 387

TWA = time-weighted average values.

For the chromium picolinate studies (NTP, 2007f), the RBC/plasma ratio did not increase as a function of dose for mice (data not shown).

Twenty-one-day data from NTP (2007f) in rats, mice, and guinea pigs at 1, 3, 10, 30, 100, and 300 mg/L Cr(VI) in drinking water showed increased chromium tissue concentrations (including in the rat femur) beginning at 10–30 mg/L. Although dose (mg/kg-day) data are not provided, evaluation of other dose data from National Toxicology Program studies for rats and mice at 21 days indicates that the dose for rats and mice at 10 mg/L Cr(VI) would be greater than 1 mg/kg-day (young growing mice will intake more water on a mg/kg basis).

Studies in rats and mice orally dosed with Cr(VI) have measured total chromium in essentially all tissues, with highest concentrations in kidney, liver, spleen, and bone (see Table C-5). Additionally, total chromium concentrations in the small intestine following oral exposure have been measured to be highest in the duodenum (the proximal small intestine) and lowest in the ileum (the distal small intestine) (see Figure C-3). This could be an indication that as Cr(VI) in drinking water traverses the small intestine, it is reduced to Cr(III) in the lumen over time.

Table C-5 Chromium in tissues (μg/g wet tissue or μg/mL blood) of mice and rats after ingesting K_2_CrO_7_ in drinking water (8 mg Cr(VI)/kg-day) for 4 or 8 weeks

Tissue | Controls | 4-wk exposure | 8-wk exposure
Mice
Liver | 0.22 ± 0.14 | 10.92 ± 5.48 | 13.83 ± 6.06
Kidney | 0.24 ± 0.14 | 3.77 ± 0.99 | 4.72 ± 0.68
Spleen | 0.53 ± 0.38 | 5.04 ± 1.45 | 10.09 ± 2.50
Femur | 0.90 ± 0.48 | 7.43 ± 1.03 | 12.55 ± 2.99
Lung | 0.24 ± 0.12 | 0.99 ± 0.10 | 1.08 ± 0.26
Heart | 0.32 ± 0.15 | 0.80 ± 0.23 | 1.02 ± 0.20
Muscle | 0.32 ± 0.23 | 1.12 ± 0.37 | 0.60 ± 0.25
Blood | 0.14 ± 0.05 | 0.71 ± 0.07 | 0.42 ± 0.04
Rats
Liver | 0.19 ± 0.14 | 3.32 ± 0.93 | 3.59 ± 0.73
Kidney | 0.34 ± 0.20 | 8.62 ± 2.40 | 9.49 ± 4.38
Spleen | 0.43 ± 0.20 | 3.65 ± 1.87 | 4.38 ± 0.84
Femur | 1.00 ± 0.46 | 1.85 ± 0.46 | 1.78 ± 0.99
Lung | 0.39 ± 0.43 | 1.10 ± 0.38 | 0.67 ± 0.24
Heart | 0.38 ± 0.22 | 0.52 ± 0.12 | 1.05 ± 0.19
Muscle | 0.24 ± 0.14 | 0.19 ± 0.10 | 0.17 ± 0.10
Blood | 0.19 ± 0.17 | 0.73 ± 0.15 | 0.58 ± 0.13

Source: Kargacin et al. (1993).

Figure C-3 Mean concentration of total chromium in GI tract tissues of mice and rats following exposure to 180 mg/L Cr(VI) in drinking water for 90 days [approximately 31.9 and 20.5 mg/kg-day Cr(VI) for mice and rats, respectively].

Data from Kirman et al. (2012).

O'Flaherty and Radike (1991) exposed rats to Cr(VI) or Cr(III) at concentrations of 200 μg/m3 via aerosol inhalation (6 hours/day) or 12.9 mg/L via drinking water ingestion (ad libitum) for 40 days (with an additional 20-day recovery period of no exposure). These concentrations are within the ranges used by some Cr(VI) toxicological studies (NTP (2008) range: 5–180 mg/L Cr(VI) via drinking water; Glaser et al. (1985) range: 25–200 μg/m^3^ via inhalation). Measured chromium concentrations in the blood and lungs were higher in rats exposed to Cr(VI) via inhalation, while chromium concentrations in the liver and intestine were higher in rats exposed to Cr(VI) via drinking water. As a result, the severities of toxicological effects induced by Cr(VI) at both portal-of-entry tissues and systemic tissues may differ by exposure route.

For tissues outside the portals of entry and for urine, Cr(VI)-exposed groups exhibited higher chromium levels than Cr(III)-exposed groups (which is consistent with higher systemic absorption of Cr(VI)). For tissues at or near the portals-of-entry (lung for inhalation, intestine for oral ingestion), chromium concentrations were comparable or higher for Cr(III) groups when compared with Cr(VI) groups. This could indicate higher localized clearance of Cr(VI) from portal tissues into blood via absorption. Chromium excretion in feces following oral ingestion of either Cr(VI) or Cr(III) was comparable (fecal chromium can be due to both elimination of systemic chromium and the passing of unabsorbed chromium). All exposure groups (either Cr(VI) or Cr(III)) exhibited higher chromium concentrations than control groups (see Tables C-6 and C-7).

Table C-6 Summary of oral and inhalation data from O’Flaherty and Radike (1991)

Study day | Lung μg Cr/g | Liver μg Cr/g | Intestine μg Cr/g | Kidney μg Cr/g | Muscle μg Cr/g | Blood ng Cr/g | Urine μg Cr/d | Feces mg Cr/d
Inhalation Cr(VI) (200 μg/m^3^ 6 h/d)
2 | 1.95 | nd | 1.10 | nd | nd | 42.5 | 0.520 | nd
5 | 5.10 | 0.060 | 1.12 | 0.217 | nd | 58.4 | 0.207 | nd
10 | 7.53 | 0.062 | 1.37 | 0.237 | nd | 73.8 | 0.266 | 0.018
20 | 13.3 | 0.066 | 2.36 | 0.310 | 0.047 | 72.8 | 0.135 | 0.048
40 | 24.3 | 0.089 | 3.24 | 0.580 | 0.054 | 75.7 | 0.047 | 0.082
60 | 13.0 | 0.038 | 0.820 | 0.137 | 0.027 | 39.8 | 0.012 | nd
Ingestion Cr(VI) (12.9 mg/L ad libitum)
2 | nd | 0.209 | 15.5 | 0.249 | nd | 9.00 | 0.622 | 0.997
5 | nd | 0.372 | 22.7 | 0.588 | nd | 11.8 | 1.79 | 0.835
10 | nd | 0.585 | 14.4 | 1.60 | nd | 18.5 | 2.01 | 0.949
20 | 1.17 | 1.18 | 29.0 | 1.71 | 0.077 | 48.9 | 3.08 | 0.977
40 | 0.650 | 1.50 | 6.80 | 1.90 | 0.103 | 58.3 | 2.19 | 1.51
60 | 0.450 | 0.509 | 0.830 | 0.634 | 0.070 | 11.3 | 0.217 | nd
Inhalation Cr(III) (200 μg/m^3^ 6 h/d)
2 | 3.43 | nd | 3.57 | nd | nd | 61.5 | 0.215 | 0.028
5 | 8.43 | nd | 4.19 | nd | nd | 64.8 | 0.101 | 0.035
10 | 17.1 | nd | 25.6 | nd | nd | 23.4 | 0.084 | 0.016
20 | 35.4 | nd | 39.4 | nd | nd | 12.0 | 0.032 | 0.032
40 | 63.7 | nd | 4.80 | nd | nd | 105.7 | 0.002 | 0.074
60 | 42.9 | nd | 0.840 | nd | nd | 89.0 | 0.001 | nd
Ingestion Cr(III) (12.9 mg/L ad libitum)
2 | nd | 0.042 | 18.3 | nd | nd | 2.48 | 0.227 | 0.821
5 | nd | trace | 17.2 | nd | nd | 3.11 | 0.065 | 0.729
10 | nd | 0.034 | 20.6 | nd | nd | 16.8 | 0.040 | 1.20
20 | nd | nd | 26.8 | nd | nd | 5.60 | 0.075 | 1.07
40 | nd | nd | 7.15 | nd | nd | 4.72 | 0.017 | 1.12
60 | nd | trace | 0.830 | nd | nd | 5.52 | nd | nd

Mean values (N = 6); nd = nondetect.

Table C-7 Summary of oral and inhalation control group data from O’Flaherty and Radike (1991)

Study day | Lung μg Cr/g | Liver μg Cr/g | Intestine μg Cr/g | Kidney μg Cr/g | Muscle μg Cr/g | Blood ng Cr/g | Urine μg Cr/d | Feces mg Cr/d
Inhalation control group
2 | nd | 0.036 | 1.13 | nd | nd | nd | 0.042 | nd
5 | nd | 0.041 | 0.64 | nd | nd | nd | 0.001 | nd
10 | nd | nd | 0.83 | nd | nd | nd | nd | nd
20 | nd | nd | 1.08 | nd | nd | nd | nd | 0.02
40 | nd | 0.041 | 1.08 | nd | nd | nd | nd | nd
60 | nd | 0.032 | 0.84 | nd | nd | nd | nd | nd
Ingestion control group
2 | nd | nd | 0.65 | 1.58 | trace | 1.5 | 0.017 | nd
5 | nd | nd | 0.83 | nd | trace | 1.6 | nd | 0.002
10 | nd | nd | 0.56 | nd | nd | 4.2 | 0.003 | nd
20 | nd | nd | 0.85 | nd | trace | 3.4 | nd | 0.013
40 | nd | 0.035 | 0.68 | nd | trace | 6.8 | 0.01 | nd
60 | nd | 0.032 | 0.72 | nd | 0.038 | 2.5 | nd | nd

Mean values (N = 6); nd = nondetect.

### C.1.3 Metabolism

Cr(VI) reduces to Cr(III) in the GI tract and in RBCs. Reduction takes place in the GI tract tissue and liver following oral exposure (due to the first-pass effect) and in pulmonary tissues following inhalation exposure. Extracellular reduction in gastric juice and in pulmonary fluids is also possible. Extracellular reduction in the lung is likely to be less effective than reduction in the GI tract, due to higher pH and lower reducing capacity. In blood, plasma reduces Cr(VI) poorly relative to RBCs (Corbett et al., 1998). Intracellular reduction of Cr(VI) (which occurs after Cr(VI) enters the cells of a susceptible tissue) is a potential pathway for metabolic activation. Reactive intermediaries and reactive oxygen species (ROS) are generated as Cr(VI) is intracellularly reduced to Cr(III).

Extracellular reduction in the stomach is expected to impact the systemic uptake of unreduced Cr(VI) and the exposure of the digestive tract epithelium. Stomach reduction may be a major source for interspecies and interindividual differences due to the strong dependence on gastrophysiology and pH. Figure C-4 illustrates the rate of reduction in human gastric juice under different pH conditions. At higher values of pH, Cr(VI) reduction occurs slowly.

Figure C-4 Reduction of Cr(VI) in samples of human gastric juice (fasted subjects) using data from Proctor et al. (2012).

Lines indicate model results by Schlosser and Sasso (2014). (Left) 2:1 dilution of stomach contents, multiple initial Cr(VI) concentrations. (Right) 10:1 dilution of stomach contents, initial Cr(VI) concentration approximately 0.1 mg/L.

The basal values of pH for humans and rodents in the fasted state are approximately 1.3 and 4, respectively (see Table C-8). Under these conditions, humans would reduce Cr(VI) more effectively than rodents. This pattern, however, is reversed during the fed state. Human gastric juice pH rises to a peak of about 6, and then decreases to baseline within 2 hours (Mudie et al., 2010). Rodent gastric juice pH decreases during the fed state, but the dynamics are not well characterized.

Table C-8 The pH of the mouse, rat, and human gastrointestinal tract

Section | Female Balb/c mice | | | | Female Wistar rats | | | | Human^a^
Section | Fed (n = 8) | | Fasted (n = 7) | | Fed (n = 5) | | Fasted (n = 5) | | Fed | Fasted
Section | Mean | SD | Mean | SD | Mean | SD | Mean | SD | Fed | Fasted
Stomach | 2.98 | 0.3 | 4.04 | 0.2 | 3.20 | 1.0 | 3.90 | 1.0 | 4.9 | 1.3
Duodenum | 4.87 | 0.3 | 4.74 | 0.3 | 5.00 | 0.3 | 5.89 | 0.3 | 5.4 | 6.0
Jejunum | 4.82 | 0.2 | 5.01 | 0.3 | 5.10 | 0.3 | 6.13 | 0.3 | 5.4–6.0 | 6.2–6.4
Ileum | 4.81 | 0.3 | 5.24 | 0.2 | 5.94 | 0.4 | 5.93 | 0.4 | 6.6–7.4
Caecum | 4.44 | 0.2 | 4.63 | 0.4 | 5.90 | 0.4 | 6.58 | 0.4 | 6.4
Proximal colon | 4.69 | 0.3 | 5.02 | 0.3 | 5.51 | 0.5 | 6.23 | 0.4 | 6.8
Distal colon | 4.44 | 0.3 | 4.72 | 0.2 | 5.77 | 0.5 | 5.88 | 0.5 | 6.8

Adapted from Mcconnell et al. (2008) and Parrott et al. (2009).

Fed-state pH values for humans represent time-weighted average values during the fed state, and not peak/maximum values occurring during a meal.

Fed-state pH values for rodents were obtained from animals that had not undergone an overnight fast, thus pH does not represent minimum values occurring during a meal.

a Standard deviations not available; summary data reviewed in Parrott et al. (2009).

Fed-state reduction kinetics have greater uncertainties, as the gastric juice will be heterogeneous and the pH fluctuation temporary. Secretion of additional gastric juices and enzymes responsible for meal digestion occurs, and various ingested food components may have different effects on reduction rate. Therefore, diet could result in high interindividual variability of fed-state reduction kinetics in the human population. This variability is apparent in ex vivo data by Kirman et al. (2016) [see U.S. EPA (2021b)]. In general, gastric juice in the fed state is believed to have a greater capacity^3^ for Cr(VI) reduction (because dietary contents such as ascorbate and secreted gastric juices may act as reducing agents). Table C-9 contains a summary of estimated Cr(VI) reducing capacities for various tissues and fluids in mice, rats, and humans. As previously noted in the absorption section, the extent of Cr(VI) reduction by components of the respiratory system is complicated by airway geometries and localized particle deposition.

Table C-9 Selected studies of Cr(VI) reduction capacities

Reference | Media (species) | Findings
Estimates of bodily fluid reduction capacity (ex vivo) ^a^
Proctor et al. (2012) | Stomach contents (rat) | Study estimate: 15.7 μg/mL
Proctor et al. (2012) | Stomach contents (mouse) | Study estimate: 16.6 μg/mL
Kirman et al. (2013) | Gastric fluid (human) | Study estimate: 20 μg/mL [based on a mean of 7 μg/mL (fasted) from this study and a median of 30 μg/mL (fed) from De Flora et al. (1987a)]
Schlosser and Sasso (2014) | Gastric fluid reanalysis (rat, mouse, human) | Reanalysis of data by Proctor et al. (2012) and Kirman et al. (2013). Rat: 4/18 μg/mL (fast/slow pool). Mouse: (3/31 μg/mL fast/slow pool). Human: 10 μg/mL (fasted-state kinetics).
De Flora et al. (2016) | Gastric fluid (human) | Colorimetric method: 10.2 ± 2.39 μg/mL (premeal) and 20.4 ± 2.61 μg/mL (post-meal) Mutagenicity assay: 13.3 ± 1.91 μg/mL (premeal) and 25.6 ± 2.89 μg/mL (post-meal)
Kirman et al. (2016) | Gastric fluid (human) | Fasted state: 2.6 ± 2.8 and 12 ± 18 μg/mL for fast and slow pools, respectively. Fed state: 0.68 ± 0.76 and 27 ± 28 μg/mL for fast and slow pools.
Kirman et al. (2016) | Gastric fluid reanalysis (rat, mouse) | Mouse: 6.1/27 μg/mL (fast/slow pool). Rat: 7.1/73 μg/mL (fast/slow pool).
De Flora et al. (1987a) | Gastric fluid (human) | 8.3 ± 4.3 μg/mL (fasting), 31.4 ± 6.7 μg/mL (fed)
Petrilli and De Flora (1982) | Saliva (human) | 1.4 ± 0.2 μg/mL
Petrilli et al. (1986) | Epithelial lining fluid (human) | 23.7 ± 15.9 μg/mL
Estimates of cellular or organ reduction capacity ^a^
De Flora et al. (1997) | Intestinal bacteria (human fecal) | 3.8 ± 1.7 μg/10^9^ bacteria (elimination via feces)
De Flora et al. (1997) | Liver (human) | 2.2 ± 0.9 μg/g liver homogenate
De Flora et al. (1997) | Blood (human) | 52.1 ± 5.9 μg/mL intact whole blood
De Flora et al. (1997) | Red blood cells (human) | 63.4 ± 8.1 μg/mL RBC lysate soluble fraction
Petrilli et al. (1986) | Pulmonary alveolar macrophages (human) | 4.4 ± 3.9 μg/10^6^ PAM S9 fraction
De Flora et al. (1987a) | Peripheral lung parenchyma (human) | 200 ± 70 μg/g lung S12 fraction
Capellmann and Bolt (1992) | Plasma (human) | 0.48–0.63 nmol/mL [at intubation of 1.5 nmol/mL Cr(VI)]
Upreti et al. (2005) | Intestinal epithelial cells and gut bacteria (rat) | Most Cr(VI) at 10 mg/L completely reduced by bacteria in 6 h. Complete reduction by some cells can take 24 h.

a Reduction capacities represent the mass of Cr(VI) that can be reduced by a tissue or fluid, per unit mass or volume of the media.

### C.1.4 Excretion

Following oral ingestion, Cr(VI) and its metabolite Cr(III) are primarily eliminated via urinary excretion (see Figures C-5 and C-6). Due to poor GI tract absorption of Cr(III), a significant amount of reduced chromium is eliminated in feces without being absorbed. Urinary excretion is also a primary pathway for elimination following inhalation exposure. Intratracheal studies in rodents have observed elevated urinary chromium, and biomonitoring studies in humans in occupations where inhalation exposure could occur have also detected elevated chromium (see Appendix C.1.6). Following chronic, low-dose oral exposure to Cr(VI), most systemic chromium is likely in the trivalent form. Site-specific clearance of Cr(VI) by reduction to Cr(III) in tissues such as the GI tract, liver, and blood is likely to be greater than systemic clearance of Cr(VI) in urine at low doses. Variability in urinary clearance rates of Cr(VI) between individuals and across species likely does not have a significant impact on toxicity under chronic low-dose exposure scenarios (since most, if not all, systemic chromium will have been reduced to Cr(III)).

Intravenous studies have indicated a significant percentage of chromium could be excreted via biliary excretion and fecal elimination; however, these elimination pathways are minor following oral ingestion (due to reduction in the stomach and liver; see Appendix C.1.6). Intravenous injection of Cr(VI) leads to high systemic concentrations that are not observed following oral exposure, and thus some distribution or metabolic mechanisms (i.e., RBC uptake and reduction) may become saturated.

Figure C-5 Urinary rates of excretion by human volunteers administered a glass of drinking water containing 2.5–5.0 mg Cr(VI) at day 2.

Data from Kerger et al. (1996).

Figure C-6 Urinary excretion rate of a human volunteer ingesting a glass of drinking water with Cr(VI) repeatedly throughout the day (0.8 mg Cr(VI) daily) for 17 days.

Data from Paustenbach et al. (1996).

### C.1.5 Physiologically Based Pharmacokinetic Models

A description of the available physiologically based pharmacokinetic (PBPK) models for Cr(VI) is available in Section 3.1.2 of the toxicological review. The PBPK model code used in this assessment (in R/MCsim) is available for download in HERO (U.S. EPA, 2022c).

Significant uncertainties exist that may be difficult to fully characterize using PBPK models. The stomach of rodents and humans will dynamically fluctuate between the fed and fasted states. This affects reaction dynamics in multiple ways. As noted in Table C-8, glandular stomach pH is decreased for the rodent during the fed state, while the opposite is true for humans. In addition to pH effects, gastric emptying is delayed in the fed state to digest food, and the volume of contents in the lumen will be increased. Gastric juice induced by food consumption may also have different reducing capacities (and ingested food itself could impact reduction kinetics). MacKenzie et al. (1959) measured absorption in fed and fasted rats following a single oral dose and observed rats in the fasted state exhibited higher tissue and urinary chromium levels than rats in the fed state. This would be consistent with more efficient Cr(VI) reduction in the fed rat than in the fasted rat. Thus, it has been demonstrated that Cr(VI) reduction in the rodent may be affected by fed status in vivo.

In addition to daily pH fluctuations, interindividual and life stage variability of stomach pH in the human population is significant. Hypochlorhydria (low stomach acid) is exhibited by an unknown fraction of the population,^4^ leading to a consistently high stomach pH (Kalantzi et al., 2006; Feldman and Barnett, 1991; Christiansen, 1968). Among adults without hypochlorhydria, 5% of men can exhibit basal pH exceeding 5, and 5% of women can exhibit basal pH exceeding 6.8 (Feldman and Barnett, 1991). That Cr(VI) reduction will be decreased for individuals with high stomach pH is expected, although the reduction rates are uncertain. Gastric juice reduction data were obtained from adults with naturally low stomach pH or stomach pH elevated by proton pump inhibitors. The gastric juice of those with high pH may be chemically or biologically different. Neonates, infants, and young toddlers generally have neutral stomach pH for the first 20–30 months, which then lowers to the normal adult range of 1–2 (Neal-Kluever et al., 2019; Bai et al., 2016).

#### C.1.5.1 Application of pharmacokinetic models for dose-response assessment

A previous PBPK application of the Kirman et al. (2013) model by Thompson et al. (2014) defined the internal dose as the average lifetime daily milligrams Cr(VI) absorbed per liter small intestine segment for the duodenum, jejunum, and ileum individually. This metric was applied to the NTP 2-year bioassay, and dose-response modeling was performed on pooled data (male and female mice, duodenum, jejunum, and ileum). Thompson et al. (2014) excluded jejunum tissue from the analysis of hyperplasia. Because of uncertainties in site-specific absorption for the human, the study authors applied total small intestinal absorption (per L small intestine) as the human dose metric for extrapolation.

Site-specific absorption in the rodent small intestine, however, is uncertain. Ingested drinking water does not evenly distribute in the small intestine lumen, but instead forms multiple discrete pockets of water that vary with time (Mudie et al., 2014). Motility in the intestine is highly variable, and the intestine secretes enzymes that can impact reduction rates. At the microscopic level, data for Cr(VI) indicates uptake might not occur uniformly in GI tract epithelial cells (Thompson et al., 2015a). The well-mixed compartment assumption is likely an inaccurate description of the system, particularly for distal regions of the intestine.

An alternative to the absorption dose metric is pyloric flux. Pyloric flux was defined by Thompson et al. (2014) to be average daily mg Cr(VI) emptied from the stomach to the small intestine, per liter small intestine. This estimate requires only the stomach portion of the gastrointestinal tract PBPK model. Fewer parameters are required to simulate pharmacokinetics in the stomach, and many of these parameters (such as gastric volume and emptying rate) are well characterized in rodents and humans. The full whole-body PBPK model by Kirman et al. (2017) contains approximately 100 PBPK parameters, and many of the fitted chemical-specific parameters have high uncertainty due to the constant presence of background Cr(III) and reduced Cr(III) in all Cr(VI) pharmacokinetics studies. The stomach-only model applied in this assessment (see Figure C-7) contains approximately 20 parameters.

Furthermore, the data underlying the ex vivo reduction model were generated under batch reaction conditions, which is similar to the stomach compartment. There is added uncertainty when extrapolating ex vivo data to the complex and dynamic intestinal compartments (which may contain different reducing agents). Uncertainties and the possible implications of these and other candidate internal dose metrics are outlined in Table C-10.

For this assessment, a hybrid PBPK-BW^3/4^ scaling approach was used for effects in the small intestine and systemic effects. The hybrid approach applied BW^3/4^ scaling to the mg/kg-day Cr(VI) escaping stomach reduction and entering the small intestine. Because the volume of the small intestine (like other tissues) varies between species by allometry, interspecies scaling by BW^3/4^ is numerically similar to scaling by small intestinal volume.

For effects in the oral mucosa, multiple dose metrics were explored. For example, the concentration of Cr(VI) ingested, scaled by the exposed oral surface areas, can be used as a dose metric. However, without such surface area data for rats, and without an oral cavity pharmacokinetic or pharmacodynamic model, it was not possible to develop these alternative dose metrics. In the absence of an adequately developed theory or information to develop and characterize an oral portal-of-entry dosimetric adjustment factor, application of BW^3/4^ scaling is recommended (U.S. EPA, 2005a, 2011).

Table C-10 Uncertainties and potential impacts of alternative dose metrics for rodent-to-human extrapolation

Dose metric | Added uncertainty | Extrapolation notes
Site-specific absorption; Daily mg Cr(VI) absorbed in a small intestine (SI) segment, per L SI segment | - Small intestine lumen not well mixed.; - Fluctuations in intestinal motility and secretions not modeled.; - Cellular uptake in epithelium not uniformly distributed.; - High variability and uncertainty for absorption of Cr(VI)/reduced Cr, perfusion of Cr(III)/ Cr(VI) from systemic plasma, absorption of background Cr(III).; - Differences in relative lengths of small intestinal segments between rodents and human preclude direct comparisons. | Human equivalent dose (HED) estimates: Similar to pyloric flux, since rapid GI uptake is assumed in all species, and human absorption is still normalized by total SI volume.; Variability assessment: Difficulty in assessing interindividual variability site-specific absorption fractions. Inconsistent dose metric basis between humans and rodents, since only total Cr(VI) absorption in whole intestine can be estimated by current human PBPK models.
Pyloric flux; Daily mg Cr(VI) emptying from the stomach to the SI, per liter SI | - Absorption not modeled (assumes 100% absorption in all species).; - Reduction in small intestine neglected. | HED estimates: Slightly higher than small intestine absorption dose metric, since this metric assumes 100% absorption for the rodent.; Variability assessment: Can only assess stomach reduction variability.
Cr(VI) lumen concentration; mg Cr(VI) in SI lumen, per liter SI lumen | - Estimates of Cr(VI) concentration in lumen contents not well characterized. | HED estimates: Similar to pyloric flux dose metric, since it normalizes the Cr(VI) mass by intestinal lumen volume (which will scale similarly as intestinal tissue volume).; Variability assessment: Difficult to assess variability.
BW^3/4^-adjusted unreduced Cr(VI) dose; Daily mg Cr(VI) emptying from the stomach, per kg BW, multiplied by (BW_a_/BW_h_)^0.25^ | - Does not explicitly incorporate volume or surface area of gastrointestinal tissue, a site of observed toxicity. | HED estimates: 10%–20% lower than pyloric flux. Normalizing unreduced Cr(VI) by a BW^3/4^ adjustment has a similar impact on HED as normalizing to intestinal volumes.; Variability assessment: Can assess only stomach reduction variability.
Stomach absorption; mg Cr(VI) absorbed in stomach tissue, per liter stomach tissue | - Estimates of Cr(VI) stomach absorption not well characterized.; - Intestinal dose metric still applied for rodent. | HED estimates: Similar to pyloric flux due to pH dependence.; Variability assessment: Difficult to assess absorption variability. Would lead to different dose metric basis between humans and rodents.
BW^3/4^ scaling; Daily mg/kg Cr(VI) ingested, multiplied by (BW_a_/BW_h_)^0.25^ | - Does not correct for species differences in Cr(VI) reduction. | HED estimates: For extrapolations in the low-dose region, would result in lower HEDs than all other approaches. For extrapolations in the high-dose region, would result in slightly lower (~20% lower) HEDs than methods listed above (due to high percentage of dose escaping for human model at high doses).; Variability assessment: Cannot directly assess inter-individual variability in pharmacokinetics.
Cr(VI) ingested concentration; Parts per million (mg/L) Cr(VI) ingested | - Does not correct for species differences in Cr(VI) reduction, tissue uptake, or tissue exposure duration.; - May require additional scaling to account for species differences in epithelial surface area and exposure time. | HED estimates: Would result in higher HEDs than most other approaches for both oral and intestinal tumors.; Feasible only for oral mucosa, prior to mixing/dilution/reduction by gastric and intestinal contents.; Variability assessment: Cannot directly assess interindividual variability in pharmacokinetics.
BW^3/4^ scaling, adjusted for target tissue volumes; Daily mg/kg Cr(VI) ingested, multiplied by: (BW_a_/BW_h_)^0.25^ × V_a_/V_h_ (V_a_ and V_h_ represent tissue volume as % total body volume) | - Does not correct for species differences in Cr(VI) reduction or tissue uptake.; - Must assume steady-state tissue delivery and clearance. | HED estimates: Difference from alternative approaches depends on organ site. Would be representative of local tissue dose. Feasible only for oral mucosa, prior to mixing/dilution/reduction by gastric and intestinal contents.; Variability assessment: Cannot directly assess interindividual variability in pharmacokinetics.

Figure C-7 Schematic of the gastric model and parameters for Cr(VI).

Parameter values and units defined in Tables C-11 (humans), C-13 (mice), and C-16 (rats).

#### C.1.5.2 PBPK model assumptions for the human

Table C-11 Final human physiological parameters for dose-response modeling and rodent-to-human extrapolation

Parameter code variable | Parameter value | Parameter source and notes
BW (kg) | 80 | Body weight. This value is chosen to maintain consistency for comparison with default approaches (such as BW^3/4^ scaling (U.S. EPA, 2005a, 2011).
VSLC (L/kg^0.75^) | 9.92 × 10^−3^ (baseline), 2.02 × 10^−3^ (fasted) | Stomach lumen volume or stomach contents volume (scaled by BW^3/4^). Baseline value (0.24 L for a 70-kg human) is based on ICRP (2002, 2006) reference values for mass of stomach contents (average of adult male and female). Fasted-state value (0.049 L for a 70-kg human, applied in the morning) is based on the mean value measured by Grimm et al. (2018): this is also the default fasted value in GastroPlus (version 9.0) software. Lognormal coefficient of variance of 0.1 applied for Monte Carlo simulations (based on GastroPlus defaults).
PHS | 1.3 (baseline), 4.9 (fed spike) | Gastric pH. Varies based on fed status (Parrott et al., 2009: Mudie et al., 2010). May be chronically elevated (>4) in some individuals (Kalantzi et al., 2006: Feldman and Barnett, 1991: Christiansen, 1968). Values of 1.3 and 4.9 obtained from Parrott et al. (2009), and decaying exponential function (e^−0.9302t^) following spike during meals estimated by digitizing data from Dressman et al. (1990). For Monte Carlo simulations, the spikes were assumed to begin up to 10 min after the breakfast/lunch/dinner oral doses and up to 30 min before (uniform distribution). Lognormal coefficient of variance of 0.12 applied to baseline for Monte Carlo simulations (based on GastroPlus defaults).
KLSD (h^−1^) | 1.39 (baseline), 2.63 (fasted) | Gastric emptying rate (1st order). Based on standard reference value of half-emptying time of noncaloric liauids in adults (30 min) by ICRP (2002, 2006). Fasted-state value based on fasted half-emptying time for water of 15.8 min Mudie et al. (2014). Lognormal coefficient of variance of 0.2 applied for Monte Carlo simulations (based on GastroPlus defaults).
RORAL (L/h) | Calculated (see text) = 0.33 (baseline) = 0.129 (fasted) | Sum of drinking water/food/saliva/GI fluid introduction into gastric compartment. This value is not set but calculated on the basis of steady-state volume of stomach contents and stomach emptying rate (see text). As a comparison, the default Kirman et al. (2017) values for the human are 0.13–0.56 L/h (varying with drinking rate). ICRP (2002, 2006) estimates the average daily generation of saliva and gastric juice in adults to be 0.133 L/h (which is approximately equal to the fasted-state RORAL). Thus, the model assumes, during a baseline 1-h ingestion event, an adult might consume approximately 0.2 L of food and/or drinking water such that the total introduction of contents to the stomach is 0.33 L.
VSIC (fraction) | 8.77 × 10^−3^ | Volume of small intestine tissue used for internal dose scaling (fraction of body weight). Used for pyloric flux estimates only. Value for a 70-kg human (~0.62 L) unchanged from Kirman et al. (2012) and Kirman et al. (2017). This is consistent with the ICRP (ICRP, 2002, 2006) value for mass of intestine wall (0.65 kg for adult males, 0.60 kg for adult females).
CRE01 (mg/L) | 10.0 (fasted); 20.0 (fed) | Reducing capacity of human gastric juice assuming a single pool of reducing agent according to the model by Schlosser and Sasso (2014). Data from De Flora et al. (2016) were used to derive fasted/fed-state values and to estimate a lognormal distribution for Monte Carlo analyses (lognormal coefficient of variance of 0.5). Model set fed-state values lasting 2 hr for the three meals (breakfast/lunch/dinner), beginning at the time of the spikes in gastric pH.

For additional kinetic parameters used in the model, see Schlosser and Sasso (2014).

GastroPlus default values used or cited alongside gastric PK parameters because they have been found consistent with values identified by literature screening and also provided estimates of population variability.

The human PBPK model was run assuming the periodic bolus exposure profile for a period of time until the internal dose metric reached steady state (7 weeks). This was done to prevent an underestimation of the internal dose, which could result from assuming continuous mg/kg-day exposure (less reducing agent depletion occurs if the dose is spread evenly over 24 hours). These drinking water assumptions are consistent with human surveys (U.S. EPA, 2019a; Barraj et al., 2009).

In addition, a change in gastric volume and gastric emptying from baseline was incorporated to account for an early morning fasted state, and a pH spike above baseline was incorporated to account for the fed state. This special fasted state was applied only in the morning, and the parameters only needed to be set shortly (1 hour) before the first ingestion because steady state in the gastric reducing agent mass balance was achieved quickly. These model assumptions are illustrated in Figure C-8.

Figure C-8 Time profiles of the average daily oral Cr(VI) dose (left) and gastric pH, reducing capacity (/10), and gastric emptying rate KLSD (right) in the human.

Exposure to Cr(VI) was assumed to occur via six discrete drinking water events of varying magnitude, occurring daily. Gastric emptying was elevated for 3 hours in the morning, beginning 1 hour prior to the first daily drinking event to simulate a morning fasted status. Gastric volume was also reduced to the fasted-state value during this time (not shown). Gastric pH was spiked to a value of 4.9 (which decreased exponentially) near the three other large drinking water events (to simulate breakfast, lunch, and dinner fed status). Elevation of the reducing capacity (lasting 2 hours) also occurred at the time of the spikes in pH. For Monte Carlo simulations, a uniform distribution was applied to the timing of the pH and reducing capacity spikes.

Local sensitivity analyses were performed on selected model parameters at a lower dose level and an upper dose level. The sensitivity was characterized by the finite difference method, and the sensitivity coefficients represent the ratios of the relative change in the response variable (internal dose) to the relative change in the independent variable (parameter). For the human model, the sensitivity of the internal dose to kinetic parameters was greater in the low-dose region. This is also illustrated by Figure C-9 for the stomach pH parameter.

Table C-12 Normalized sensitivity coefficients of human gastric model parameters with respect to pyloric flux dose metric

Parameter | Sensitivity coefficient at 0.04 mg/kg-d | Sensitivity coefficient at 0.4 mg/kg-d
CRE01 (reducing capacity of fast binary reaction, mg/L) | −1.2694 | −0.7297
KLSD (gastric emptying rate, h^−1^) | 0.7661 | −0.0129
VSLC (baseline stomach lumen volume, fraction of BW) | −0.2226 | −0.5593
VSLCFAST (fasted-state stomach lumen volume, fraction of BW) | −0.3550 | −0.1289
K (rate constant for fast binary reaction, L/mg-h) | −1.1920 | −0.0409
PHS (baseline) | 0.2197 | 0.0143
PHSF (fed-state spike)^a^ | 5.1534 | 0.2461

Note: This model analysis incorporated only two pH spikes (lunch and dinner) and held CRE01 constant (no fed-state increase to 20 mg/L).

a To avoid simulation artifacts caused by TSPIKE and ingestion time occurring at same time, the values of TSPIKE were set to 5 minutes prior to water ingestion events.

Figure C-9 (a) Percent Cr(VI) escaping stomach reduction (and being emptied to the small intestine) as a function of oral Cr(VI) dose for different values of baseline fasted-state stomach pH (human). (b) Pyloric flux as a function of oral dose for the human.

The pH spike was set to begin 10 minutes prior to Cr(VI) ingestion for the three meals in this example (for human equivalent dose calculations, this is a random variable).

Figure C-10 Monte Carlo analysis (20,000 iterations) of the human equivalent dose at selected values of the internal dose.

Model assumes three daily spikes in pH during the three large ingestion events and elevated gastric emptying/reduced gastric volume during early morning ingestion event. All simulations assume lognormal distributions for the baseline and fasted parameters, with coefficient of variance (CV) of 10% for stomach volume, 12% for baseline pH, 50% for fed and fasted reduction capacities, and 20% for stomach emptying. A uniform distribution was applied to the timing of each pH spike to allow for the oral dose to occur up to 30 minutes after the start of a large meal (pH spike), and up to 10 minutes before. All other parameters held constant. (Left) Human equivalent dose (HED) at pyloric flux 4 mg/L-d. (Right) Human equivalent dose (HED) at pyloric flux 0.1 mg/L-d.

To evaluate the potential impact of pharmacokinetic susceptibility on adult populations with high stomach pH, simulations were run using altered assumptions for baseline and fed-state pH (see Table C-13). These simulations included estimating the HED for low-dose and high-dose internal dose PODs. Standard default population simulations assumed a mean baseline pH of 1.3 and a fed spike of 4.9. The PHS = 4 population assumed a mean baseline pH of 4 and a fed spike pH of 4.9. For all simulations, the baseline pH had a lognormal distribution with a coefficient of variance of 0.12.

Although a fed-state pH spike was maintained for the high pH population, some uncertainty exists regarding the daily pH profile in response to meals. The study in healthy elderly subjects by Russell et al. (1993) observed that for individuals with high baseline pH, some exhibited minimal pH change with meals, while others exhibited a decrease in pH with meals.

Table C-13 Human equivalent dose (mg/kg-day) outputs of 20,000 Monte Carlo simulations of varying baseline pH populations using the BW^3/4^-adjusted Cr(VI) dose escaping stomach reduction

Internal dose POD (mg/kg-d) | Model assumption | Mean HED (mg/kg-d) | SD (mg/kg-d) | Lowest 1% HED (mg/kg-d)
0.03 | Default | 0.328 | 0.0942 | 0.171
| PHS = 4 | 0.220 | 0.102 | 0.0596
0.001 | Default | 0.0320 | 0.00945 | 0.0165
| PHS = 4 | 0.0178 | 0.0179 | 0.00204
0.000732 | Default | 0.0237 | 0.00708 | 0.0121
| PHS = 4 | 0.00943 | 0.00404 | 0.00269

At high internal dose (which is most relevant for cancer extrapolation), the mean value for the HED of the pH = 4 population is approximately 33% lower than the HED of the default pH = 1.3 population. At low internal dose (which is most relevant for noncancer extrapolation), the mean value for the HED of the pH = 4 population is approximately 44% lower than the default. The value of the lowest 1% for the default assumption (0.0165 mg/kg-day), however, is still slightly lower than the mean value of the pH = 4 population (0.0178 mg/kg-day), meaning the pharmacokinetic approach is protective for the average of that group.

For values lower than 0.001 mg/kg-day (i.e., 0.000732 mg/kg-day), the mean HED of the pH = 4 population (0.00943 mg/kg-day) is 22% less than the lowest 1% HED of the pH = 1.3 population (0.0121 mg/kg-day). This is because at very low doses, the model is more sensitive to differences in pH. However, all internal-dose PODs for this assessment (which are used to derive human equivalent doses) are higher than 0.001 mg/kg-day. As a result, the pharmacokinetic approach (which uses the lowest 1% value) is protective of the pH = 4 population.

The pharmacokinetics results for all PODs can be compared with BW^3/4^ scaling without pharmacokinetic adjustment for interspecies Cr(VI) reduction (see Appendix D.3). By not accounting for extracellular Cr(VI) reduction in either the rodent (gastric pH = 4.5) or the human (gastric pH = 1.3), the default scaling approach technically applies to the most sensitive population in terms of pharmacokinetics (i.e., a human population in which gastric pH = 4.5 and gastric juice reduction capacity is equivalent to that of the rodent). However, this does not consider the extreme case in which human pH is significantly higher than that assumed for the rodent (pH > 4.5).

Applying BW^3/4^ adjustment in accordance with (U.S. EPA, 2005a, 2011) and applying an intraspecies uncertainty factor (UF_H_) of 3 (rather than 10, because the default approach implicitly accounts for the most sensitive pharmacokinetic population) is protective of the population that has high pharmacokinetic susceptibility. As noted in Appendix D.3, this specifically applies to the low-dose region, for which the model is most sensitive to gastric pH. At high doses, for which the model is more sensitive to gastric reducing capacity, the lower 1% predictions from Monte Carlo simulations using the pharmacokinetic model are more health protective than BW^3/4^ scaling.

Appendix D.3 contains a table of the RfD derivation using default approaches (no gastric reduction adjustment) and with UF_H_ = 3.

#### C.1.5.3 PBPK model assumptions for the mouse

PBPK simulations were run assuming standard adult rodent physiology (see Table C-14), with circadian drinking water pattern (see Figure C-11), until steady-state was achieved (7 weeks). This was done to prevent an underestimation of the internal dose, which could result from assuming continuous mg/kg-day exposure (less reducing agent depletion occurs if the dose is spread evenly over 24 hours).

Table C-14 Final mouse PBPK parameters for dose-response modeling and rodent-to-human extrapolation

Parameter code variable | Parameter value | Notes
BW (g) | 50 | Body weight. The time-weighted average body weight of mice in the NTP 2008 bioassays. Additional study-specific values of rodent body weight were used when necessary.
VSLC (L/kg^0.75^) | 0.00696 | Volume of the stomach lumen contents (scaled by BW^3/4^). Based on Mcconnell et al. (2008) “comfortably full” volume (0.37 mL in 18–22g mice). For a 50 g mouse, this equates to a stomach volume of 0.736 mL.
PHS | 4.5 | Gastric pH. Value unchanged from Kirman et al. (2012) and Kirman et al. (2017) since reduction data in mice are available only for pH 4.5 (and thus, confidence is highest for the mouse reduction rate at that pH). This parameter can vary with both fed status and stomach region (forestomach vs. glandular stomach) (Mcconnell et al., 2008; Kohl et al., 2013; Browning et al., 1983; Beasley et al., 2015). The reduction model used in this assessment by Schlosser and Sasso (2014) performs well for the available data of Cr(VI) reduction in rodent gastric juices.
KLSD (h^−1^) | 4.33 | Gastric emptying rate (1st order). Value changed from default value of 9.4 h^−1^ by Kirman et al. (2012) Kirman et al. (2017). Based on the default fed-state GastroPlus stomach transit time of 19.2 min. This is consistent with the literature, which estimates a half-emptying time for liquids in mice of approximately 10 min (Symonds et al., 2002; Roda et al., 2010; Miyasaka et al., 2004; Bennink et al., 2003) (see Table C-27). This parameter can vary based on fed status and gastric and dietary contents.
RORAL (mL/h) | 3.2 (calculated) | Sum of drinking water/food/saliva/GI fluid introduction into gastric compartment. This value is not set but calculated on the basis of steady-state volume of stomach contents and stomach emptying rate (see text). As a comparison, the value of RORAL by Kirman et al. (2017) for the NTP (2008) data ranges from 0.65 to 6.2 mL/h (varying with drinking rate). In Kirman et al. (2017), this parameter was the sum of multiple individually defined rates that had high uncertainty and variability. The value for the gastric fluid (acid) production component defined in the (Kirman et al., 2012; Kirman et al., 2017) models was a central estimate by Thompson et al. (2011a) based on (Wang et al., 2000; Tibbitts, 2003; Ito and Schofield, 1974; Friis-Hansen et al., 1998). Those data varied significantly with time, fed status, and other factors, and the exact source of the Thompson et al. (2011a) estimate could not be determined. The saliva secretion rate component defined in (Kirman et al., 2012; Kirman et al., 2017) was based on a model by Timchalk et al. (2001), although it was not a measured parameter (it was instead calibrated to lead pharmacokinetic data). Values defined in (Kirman et al., 2012; Kirman et al., 2017) for the food and water intake component of RORAL were study specific.
VSIC (fraction) | 0.0393 | Volume of small intestine (fraction of body weight). Used for pyloric flux estimates only. Value unchanged from Kirman et al. (2012), which is based on fractional tissue volumes of the duodenum, jejunum, and ileum measured in that study. Value is consistent with Brown et al. (1997) (which estimates it to be 2%–4% of body weight).

For additional kinetic parameters used in the model, see Schlosser and Sasso (2014).

Figure C-11 Distribution of the average daily oral Cr(VI) dose in the mouse.

Exposure to Cr(VI) was assumed to occur ad libitum in drinking water according to observed circadian drinking water data (Yuan, 1993).

Local sensitivity analyses were performed on selected model parameters at a lower dose level and an upper dose level using the finite difference method. For the rodent model, dose region had less effect on model sensitivity (see Table C-15). However, the rodent model was very sensitive to changes in pH (see Figure C-12), since the kinetic function of rate vs. pH by Schlosser and Sasso (2014) is steep in the region around pH 4.5. Ex vivo rodent kinetic data are available only at pH = 4.5 (mice) and pH = 4.38 (rats) Proctor et al. (2012). The kinetic model by Schlosser and Sasso (2014) adequately fits the rodent ex vivo data at these values of pH. Because the true value of the rodent whole stomach pH (glandular stomach + forestomach) during the NTP (2008) 2-year bioassay is uncertain, and because no ex vivo data are available for rodent kinetics at low pH, the model will be run only at pH = 4.5 (mice) and pH = 4.38 (rats) when used for the dose-response assessment. These values are fair approximations for the model since they fall within the range observed in rodents, but they are not without uncertainty (Mcconnell et al., 2008; Kohl et al., 2013; Browning et al., 1983; Beasley et al., 2015).

Table C-15 Normalized sensitivity coefficients of mouse gastric model parameters with respect to pyloric flux dose metric

Parameter | Sensitivity coefficient at 0.302 mg/kg-d | Sensitivity coefficient at 8.89 mg/kg-d
CRE01 (reducing capacity of fast binary reaction, mg/L) | −0.5083 | −0.3009
CRE02 (reducing capacity of slow binary reaction, mg/L) | −0.3576 | −0.6615
KLSD (gastric emptying rate, h^−1^) | 0.8101 | 0.3231
VSLC (stomach lumen volume, fraction of BW) | −0.0301 | −0.3243
K (rate constant for fast binary reaction, L/mg-h) | −0.5173 | −0.1001
KS (rate constant for slow binary reaction, L/mg-h) | −0.3582 | −0.5428
KVF (rate constant for slowest binary reaction, L/mg-h) | −0.0031 | −0.0077
PHS (stomach pH) | 7.8453 | 6.0116

Figure C-12 (a) Percent Cr(VI) escaping stomach reduction (and being emptied to the small intestine) as a function of oral Cr(VI) dose for different values of baseline stomach pH (mouse). (b) Pyloric flux for the mouse using standard assumption at PHS = 4.5.

Because the internal dose is very close to linear (see Figure C-12), benchmark dose modeling can be performed on the basis of the external oral dose, and PBPK model adjustments can be done in subsequent steps. Table C-16 below lists the predicted internal doses for the (NTP, 2008) 2-year drinking water bioassay. Table C-17 lists average daily internal doses for the female mouse (F0 dams) during the NTP (1997) bioassay.

Table C-16 Lifetime average daily internal doses for the mouse during the NTP (2008) 2-year bioassay of sodium dichromate dihydrate

Cr(VI) (mg/L) | TWA doce (mg/kg-d) | Dose escaping (mg/kg-d) | Pyloric flux (mg/L-d)
Females
5 | 0.302 | 0.0463 | 1.18
20 | 1.18 | 0.197 | 5.00
60 | 3.24 | 0.636 | 16.2
180 | 8.89 | 2.31 | 58.7
Males
5 | 0.450 | 0.0700 | 1.78
10 | 0.914 | 0.149 | 3.79
30 | 2.40 | 0.443 | 11.3
90 | 5.70 | 1.29 | 32.9

TWA dose: Time-weighted average daily dose.

Table C-17 Average daily internal doses for the female mouse (F0 dams) during the NTP (1997) bioassay

TWA doce (mg/kg-d) | Dose escaping (mg/kg-d)
11.6 | 3.09
24.4 | 8.61
50.6 | 24.8

BW = 24 g.

#### C.1.5.4 PBPK model assumptions for the rat

Table C-18 outlines the kinetic parameters used for a standard rat. For additional kinetic parameters used in the model, see Schlosser and Sasso (2014).

Table C-18 Final rat PBPK parameters for dose-response modeling and rodent-to-human extrapolation

Parameter code variable | Parameter value | Notes
BW (g) | 450/395 (males); 260/215 (females) | Body weight (2-yr/12-mo). The time weighted average body weights of male and female rats in the NTP 2008 bioassays. Additional study-specific values of rodent body weight were used when necessary.
VSLC (L/kg^0.75^) | 0.0125 | Volume of the stomach lumen contents (scaled by BW^3/4^). Based on Mcconnell et al. (2008) “comfortably full” volume (3.38 mL for 160–190 g rats). For a 260-g rat, this yields a stomach volume of 4.55 mL. For a 450-g rat, it yields 6.87 mL.
PHS | 4.38 | Gastric pH. Value unchanged from Kirman et al. (2017), since reduction data in rats are available only for pH 4.38 (and thus, confidence is highest for the rat reduction rate at that pH). This parameter can vary with both fed status and stomach region (forestomach vs. glandular stomach) (Mcconnell et al., 2008; Kohl et al., 2013; Browning et al., 1983; Beasley et al., 2015). The reduction model used in this assessment by Schlosser and Sasso (2014) performs well for the available data of Cr(VI) reduction in rodent gastric juices.
KLSD (h^−1^) | 2.77 | Gastric emptying rate (1st order). Changed from default value of 2.4 h^−1^ defined by Kirman et al. (2012) and Kirman et al. (2017). Based on the default fed-state GastroPlus stomach transit time of 30 min. This is consistent with the literature, which estimates a half-emptying time for liquids in rats of approximately 15 min (Scarpignato et al., 1984; Purdon and Bass, 1973). This parameter can vary on the basis of fed status and gastric and dietary contents.
RORAL (mL/h) | 12–19 (calculated) | Sum of drinking water/food/saliva/GI fluid introduction into gastric compartment. This value is not set but calculated on the basis of the steady-state volume of stomach contents and stomach emptying rate (see text). As a comparison, the default value calculated by Kirman et al. (2017) for the NTP (2008) study is 4–33 mL/h (varying with drinking rate). In Kirman et al. (2017), this parameter is the sum of multiple individually defined rates that had high uncertainty and variability. The value for the gastric fluid (acid) production component defined in the (Kirman et al., 2012; Kirman et al., 2017) models was a central estimate by Thompson et al. (2011a) based on (Wallmark et al., 1985; Tibbitts, 2003; Takeuchi et al., 1998; Runfola et al., 2003; Kuwahara et al., 1990; Kitamura et al., 1999). Those data varied significantly with time, fed status, and other factors, and the exact source of the Thompson et al. (2011a) could not be determined. The saliva secretion rate component defined in (Kirman et al., 2012; Kirman et al., 2017) was based on a model by Timchalk et al. (2001), although it was not a measured parameter (it was instead calibrated to lead pharmacokinetic data). Values defined in (Kirman et al., 2012; Kirman et al., 2017) for the food and water intake component of RORAL were study specific.

Figure C-13 Ad libitum drinking water assumptions applying data from the rat (Spiteri, 1982).

PBPK simulations were run assuming standard adult rodent physiology, with circadian drinking water pattern (see Figure C-13), until steady-state was achieved (7 weeks). This was done to prevent an underestimation of the internal dose, which could result from assuming continuous mg/kg-day exposure (less reducing agent depletion occurs if the dose is spread evenly over 24 hours).

Local sensitivity analyses were performed on selected model parameters at a lower dose level and an upper dose level using the finite difference method (see Table C-19).

Table C-19 Normalized sensitivity coefficients of rat gastric model parameters with respect to average daily dose escaping stomach reduction

Parameter | Sensitivity coefficient at 0.2 mg/kg-d | Sensitivity coefficient at 7.13 mg/kg-d
CRE01 (reducing capacity of fast binary reaction, mg/L) | −0.7410 | −0.4692
CRE02 (reducing capacity of slow binary reaction, mg/L) | −0.2142 | −0.6868
KLSD (gastric emptying rate, h^−1^) | 0.8916 | 0.1877
VSLC (stomach lumen volume, fraction of BW) | −0.0410 | −0.6081
K (rate constant for fast binary reaction, L/mg-h) | −0.7010 | −0.0683
KS (rate constant for slow binary reaction, L/mg-h) | −0.2138 | −0.4880
KVF (rate constant for slowest binary reaction, L/mg-h) | −0.0046 | −0.0206
PHS (stomach pH) | 8.3698 | 5.2725

Figure C-14 (a) Percent Cr(VI) escaping stomach reduction (and being emptied to the small intestine) as a function of oral Cr(VI) dose for different values of baseline stomach pH (rat). (b) Dose escaping stomach reduction for the rat using standard assumption at PHS = 4.38.

Because the internal dose is very close to linear (see Figure C-14), benchmark dose modeling can be performed on the basis of the external oral dose, and PBPK model adjustments can be done in subsequent steps. Table C-20 lists the predicted internal doses for the (NTP, 2008) 2-year drinking water bioassay. This table includes values calculated at the 1-year timepoint for males. Additionally, BMD modeling was performed on the basis of internal dose to evaluate the difference between PODs derived from internal-dose and external-dose BMD modeling (difference was 1.2% for liver ALT).

Table C-20 Lifetime average daily internal doses for the rat during the NTP (2008) 2-year bioassay of sodium dichromate dihydrate (pH = 4.38)

Cr(VI) concentration | TWA dose (mg/kg-d) at 2 yr | Cr(VI) dose escaping stomach reduction (mg/kg-d) at 2 yr | TWA dose at 1 yr (mg/kg-d) | Cr(VI) dose escaping stomach reduction at 1 yr (mg/kg-d) | TWA dose at 90 d (mg/kg-d) | Cr(VI) dose escaping stomach reduction at 90 d (mg/kg-d)
Females
5 | 0.248 | 0.0195 | 0.0294 | N/A | N/A | N/A
20 | 0.961 | 0.0881 | 1.14 | N/A | N/A | N/A
60 | 2.60 | 0.339 | 3.01 | N/A | N/A | N/A
180 | 7.13 | 1.66 | 8.28 | N/A | N/A | N/A
Males
5 | 0.200 | 0.0156 | 0.237 | 0.0187 | 0.401 | 0.0325
20 | 0.796 | 0.0721 | 0.938 | 0.0875 | 1.58 | 0.165
60 | 2.10 | 0.264 | 2.49 | 0.336 | 4.16 | 0.699
180 | 6.07 | 1.40 | 7.19 | 1.79 | 11.7 | 3.66

TWA BW at 2 years: 450 g (males), 260 g (females). TWA BW at 1 year: 395 g (males), 215 g (females). TWA BW at 90 days: 246 g (males). No relevant dose-response 1-year data for female rats. Oral doses assumed the circadian rat drinking water profile (Spiteri, 1982).

Table C-21 Lifetime average daily internal doses for the rat during the NTP (2007f) 90-day bioassay of sodium dichromate dihydrate (pH = 4.38)

Cr(VI) concentration | TWA dose (mg/kg-d) at 90 d | Cr(VI) dose escaping stomach reduction (mg/kg-d) at 90 d
Females
0 | 0 | 0
21.8 | 1.74 | 0.181
43.6 | 3.49 | 0.500
87.2 | 6.28 | 1.26
174.5 | 11.5 | 3.33
349 | 21.3 | 9.00
Males
0 | 0 | 0
21.8 | 1.74 | 0.188
43.6 | 3.14 | 0.446
87.2 | 5.93 | 1.22
174.5 | 11.2 | 3.38
349 | 20.9 | 9.22

BW_A_ = 0.160 kg (females), 0.232 kg (males).

Table C-22 Comparison of internal-dose points of departure based on external-dose BMD modeling and internal-dose BMD modeling

Species/sex | Dataset | BMR | Internal^a^ BMD mg/kg-d | Internal^a^ BMDL mg/kg-d (linear model)^b^ | Internal dose derived from external BMDL_1RD_ (exponential 2 model)^b^ | % diff.
Rat/M | Liver ALT (NTP, 2008) | 1RD | 0.214 | 0.166 | 0.168 | 1.2

a Dose escaping stomach reduction in rodent (mg/kg-d) estimated by pharmacokinetic modeling.

b Data were amenable to BMD modeling with the highest dose omitted. Note: the time weighted average daily doses used in this example were slightly (<5%) different than the final calculated values used elsewhere in this assessment. As a result, the value deviates slightly from the final internal dose POD presented elsewhere.

#### C.1.5.5 General PBPK model considerations

Model estimates are based on physiological parameters near the standard reference values in each species. Chromium ingestion can be associated with water intake (which increases volume of the stomach contents and potentially dilutes reducing agent) and food intake (which increases gastric juice production and volume and alters pH and gastric emptying).

Simulations in the human and the rodents assume RORAL (total gastric contents rate into stomach, L/hr) is equal to KLSD (gastric emptying rate, h^−1^) multiplied by VSL (gastric contents volume, L). The Kirman et al. (2017) model instead calculates gastric contents volume as a function of RORAL and KLSD. For rats and humans, the model produces reasonable values for stomach contents volume, but for mice, the stomach volume is outside the range measured by Mcconnell et al. (2008). Since the individual-level components of the RORAL parameter (gastric juice production, saliva production, and time-varying water and food ingestion) have higher uncertainty than stomach volume (which is a single, measurable parameter), this assessment defines a value for VSL rather than for RORAL.

Previously, in Kirman et al. (2012) and Sasso and Schlosser (2015), a mathematical discrepancy existed since the chromium concentration was determined by the volume of the stomach lumen, while the reducing agent concentration was determined by volume of stomach contents (which was a function of RORAL and gastric emptying). The volumetric basis for Cr(VI) and reducing agent concentrations should be the same because they coexist in the same reaction volume. If RORAL, gastric contents volume, and gastric emptying are related by a mass balance equation, the volumetric basis for concentration calculation is the same for Cr(VI) and the reducing agent, and the discrepancy is resolved. Simulating gastric kinetics using physiology that is not harmonized (i.e., with the discrepancy between gastric lumen volume and steady-state gastric contents volume) leads to high internal doses in all species (i.e., >20%–70% of the dose escaping reduction). This is because the mass balance of the gastric contents consistently produces a volume significantly lower than the stomach lumen volume. The rate of reduction is dependent on the chromium concentration, and the predicted chromium concentration may be overdiluted if chromium mass is divided by lumen volume instead of gastric contents volume.

If most of the Cr(VI) that escapes the stomach reduction is assumed to be absorbed into the system (which is reasonable given the high pH and surface area in the small intestine, and rapid uptake of Cr(VI)), the modeling results in this assessment agree with in vivo pharmacokinetic studies. Studies in rodents (Thomann et al., 1994; Fébel et al., 2001) have estimated that approximately 10% of an ingested Cr(VI) dose might ultimately be absorbed into the system as Cr(VI) when compared with Cr(III) (which is absorbed less readily). In humans, the Cr(VI) absorbed following oral ingestion has been estimated to be lower (Paustenbach et al., 1996; Kerger et al., 1996; Kerger et al., 1997; Finley et al., 1997). An in vitro Cr(VI) bioaccessibility study estimated a significant percentage of Cr(VI) may be bioaccessible in humans at pH > 3, even at low doses, but bioaccessibility decreases sharply at lower values of pH (Wang et al., 2022).

### C.1.6 Literature Overview of Studies Identified as ADME

Table C-23 presents a summary of studies that contain primary in vivo pharmacokinetic data in rats, mice, and humans following Cr(VI) exposure. These tables indicate whether studies contained concurrent data for Cr(III) exposure, as these data are informative in directly assessing differences between Cr(VI) and Cr(III) kinetics.

Table C-24 presents a summary of studies that contain in vitro or ex vivo data related to absorption and/or reduction in the GI tract or blood. These studies primarily focus on quantitative analysis of kinetics. Tables C-23 and C-24 also indicate whether a study has been used quantitatively or qualitatively in the development of any previously published PBPK model.

Table C-25 presents a summary of studies related to the distribution and reduction of Cr(VI) in a variety of systems. These studies differ from those in Table C-24 in that the experiments primarily focused on mechanisms by modifying the enzymes or transport carriers in the systems tested. Tables C-23 to C-25 include only those studies pertaining primarily to Cr(VI) pharmacokinetics and do not include studies that primarily address Cr(VI) toxicity.

Table C-26 presents a summary of studies related to human biomonitoring of Cr(VI) in industrial or volunteer populations that focus primarily on data on biomarkers of exposure as opposed to human health effects. These differ from the human studies in Table C-23 in that the exposure profiles are not controlled or may be difficult to estimate.

All tables in this section are slightly modified from those released in September 2014 due to a rescreening of articles from the literature search, addition of new studies, and public comments.

Table C-23 In vivo Cr(VI) pharmacokinetic studies

Reference | Species | Tissue matrices and notes | Cr(III) control^a^
Intravenous (IV) injection
Cavalleri et al. (1985) | Rat | Bile, whole blood, and plasma. 2-hr time-course data. | N
Cikrt and Bencko (1979) | Rat | Total body burden, urine, feces, liver, kidneys, plasma, and GI tract wall. 24-hr time-course data. | Y
Marouani et al. (2012) | Mouse | Fetus, placenta, liver, kidney, serum. Injection to pregnant mice at d 13 or 16 of gestation. Spot sample 1-hr after injection. | Y
Liu et al. (1994); Liu et al. (1996) | Mouse | Blood, liver, heart, spleen, kidney, and lung. Kinetics of pentavalent chromium (Cr V) following Cr VI reduction. 60-min time-course data. | N
Norseth et al. (1982) | Rat | Bile and liver. 2-hr time-course data. | Y
Merritt et al. (1989) | Hamster | Urine, plasma, RBC, kidney, spleen, liver, and lung. Monthly or weekly injections. 5-wk postexposure time-course data. | N
Richelmi et al. (1984) | Rat | Blood. In vivo Cr VI measurement of reduction and capacity. Spot sample at 1-min postexposure. | N
Intraperitoneal (IP) injection
Afolaranmi and Grant (2013) | Rat | Liver, kidney, heart, brain, lung, spleen, testes, blood, urine, and feces. Effect of ascorbic acid. Spot sample 24 hr postexposure. | N
Balakin et al. (1981) | Rat | Liver, whole body (excluding liver), wall of cecum, chime of cecum, urine, and feces. Spot sample 30 min postexposure. This is a chelation study that included a Cr VI-only group. | Y
Bryson and Goodall (1983) | Mouse | Total body burden, urine, and feces. 21 d time-course data. | Y
Bulikowski et al. (1999) | Rat | Skin. Injections over 30 d. Micronutrient interaction study with Cr Vi-only groups. | N
Devoy et al. (2019) | Rat | Plasma, RBC, and urine. Single IV injection. Multiple doses and time-course data (hourly, daily, to 90 d for some groups). | Y
Döker et al. (2010) | Mouse | Liver, kidney, brain, lung, heart, and testis. Effect on other essential metals analyzed. Spot sample at 12 hr postexposure. | N
Manzo et al. (1983) | Rat | Bile, plasma, liver, urine, feces, stomach, small intestine, and large intestine. Detection in GI tissues postexposure. 2-hr time-course data. | Y
Ogawa et al. (1976) | Mouse | Urine, feces, and whole body. Spot sample data at 48 hr postexposure. | Y
Sankaramanivel et al. (2006) | Rat | Bone (vertebrae, femur, and calvaria). IP injections once per d for 5 d. | N
Suzuki (1988b) | Rat | Plasma, whole blood. 60-min time-course data. | N
Ueno et al. (1995) | Mouse | Liver. Total Cr and pentavalent (Cr V). 12-hr time-course data. | N
Minigaliyeva et al. (2014) | Rat | Liver, kidney, spleen, and brain. Injection 3 times per wk (less than 7 wk). Spot sample at end of study. | N
Yamamoto et al. (1981) | Mouse, rabbit | Urine, feces, blood, and liver. Single IP (50 or 200 μMol/kg), time-course data over undetermined length (at least 7 d). | N
Subcutaneous injection
Mutti et al. (1979) | Rat | Urine, spleen, liver, renal cortex, renal medulla, lung, and bone. 48-h (single exposure) and 12-wk (repeated exposure) time-course data. | N
Pereira et al. (1999) | Mouse | Liver, kidney, and spleen. Multiple injections (once per wk for varying number of weeks). Spot sample at 1 wk after last exposure. | N
Yamaguchi et al. (1983) | Rat | Urine, feces, lung, liver, kidney, brain, heart, spleen, testis, muscle, hair, and blood. 30 d time-course data. | Y
Dermal
Corbett et al. (1997) | Human | Urine, RBC, and plasma. 4 d time-course data.
Oral
Collins et al. (2010) (National Toxicology Program studies); NTP (2007f); (2008) | Rat, mouse, Guinea pig | Urine, feces, erythrocytes, plasma, liver, kidney, glandular stomach, and forestomach (2 yr study). Multiple studies. Blood, kidney, and femur (21 d study in rats only). No mouse urinary data for chronic Cr III study. Chronic Cr III/Cr VI data at multiple sacrifice times (after 2 d washout period). Time-course (2-d) gavage data (urine/feces only) for Cr III only. Guinea pig data only at 21 d. | Y
Donaldson and Barreras (1966) | Human, rat | Urine, feces. Oral dose and perfusion to the small intestine (bypassing stomach reduction) to assess Cr VI reduction and absorption. | Y
Iranmanesh et al. (2013) | Rat | Liver, kidney, intestine, spleen, and testicle. Drinking water exposure for 60 d. Spot sample after 7 d washout period. This is a chelation study that included a Cr VI-only group. | N
Finley et al. (1996); (1997) Kerger et al. (1996); (1997) Paustenbach et al. (1996) | Human | Human pharmacokinetic volunteer studies. Urine, plasma, and RBC. Multiple exposure scenarios (i.e., single and repeated doses). Time-course data over multiple days before, during, and after exposure. | Y
Kirman et al. (2012) | Rat, mouse | Oral cavity, stomach, duodenum, jejunum, ileum, plasma, red blood cell, and liver. Spot sample at end of 90 d exposure period. | N
Saxena et al. (1990) | Rat, mouse | Oral (drinking water) study in pregnant rodents. Maternal blood, placenta, and fetus. | N
Sutherland et al. (2000) | Rat | Bone, kidney, liver, and testes. Exposure for 44 wk, with spot samples 4–6 d postexposure (no time-course data). | N
Thomann et al. (1994) | Rat | Blood, liver, kidney, spleen, bone, and total carcass. 6-wk exposure followed by 140 d postexposure. Time-course data of pre- and postexposure periods. | N
Wang et al. (2015) | Rat | Heart, kidney, spleen, liver, lung, brain, stomach, testis, and duodenum. Spot sample at end of 4-wk exposure period (after overnight starvation). | N
Witmer et al. (1989) | Rat | Blood, kidney, spleen, liver, lung, brain, and testes. Spot sample at end of 7- and 14 d exposure periods (24 hr after last treatment). | N
Yawets et al. (1984) | Rat | Liver. Single dose, spot sample. | N
Intratracheal
Bragt and van Dura (1983) | Rat | Urine, feces, blood, heart, lungs, spleen, kidneys, liver, pancreas, testes, and bone marrow (femur).; 50 d postexposure time-course data for whole-body retention and blood. 10 d time-course data for urine and feces. Spot sample data for other tissues at 50 d postexposure. Three different Cr VI formulations. | N
Edel and Sabbioni (1985) | Rat | Lung, trachea, kidney, liver, spleen, pancreas, epididymis, testes, brain, heart, thymus, femur, skin, fat, muscle, stomach, small intestine, large intestine, blood, plasma, RBC, lung lavage, urine, and feces. Spot sample in tissues at 24 hr postexposure. 7 d time-course data of excretion. | Y
Perrault et al. (1995) | Sheep | Bronchoalveolar lavages (BAL), lung. Exposure and analysis of particulate forms. 30 d time-course data for BAL; spot sample for lung at d 30. | Y
Gao et al. (1993b) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=79048) | Rat | Blood, plasma, urine, and lymphocytes. 72-h time-course data. | Y
Vanoirbeek et al. (2003) | Rat | Lung, liver, plasma, RBC, and urine. Spot tissue samples at 2 and 7 d postexposure. 7 d time-course data of urinary excretion. | Y
(Wiegand et al., 1984a; 1987; 1988) | Rabbit | Blood, plasma, RBC, liver, kidneys, urine, lung, and trachea. 4-h postexposure time-course data. | Y
Song et al. (2014) | Rat | Blood, plasma, RBC, and lung. Once-per-wk exposure for 28 d. Spot sample after overnight fast.
Inhalation
Antonini et al. (2010) | Rat | Lung, heart, kidney, liver, spleen, and brain. Exposure to welding fume at 1, 4, 25, 105 d. | N
Cohen et al. (1997) | Rat | Lung (and lung fluids/subcompartments), liver, kidney, and spleen. Exposure for 5 hr/d, 5 d/wk. Spot samples at 2 or 4 wk (24 hr postexposure) | N
(Kalliomäki et al., 1982; 1983) | Rat | Blood, liver, kidneys, stomach, spleen, and lung. Welding arc fumes (with chromium concentration measurement). Exposures vary in hr per d or number of days exposed. Spot samples at 24 hr postexposure. 106 d time-course data for elimination study. | N
Suzuki et al. (1984) | Rat | Lung, whole blood, plasma, RBC, kidney, spleen, heart, liver, and testis. Aerosolized Cr III and Cr VI. Exposure for 2 or 6 hr. 7 d time-course data. | Y
Multiple routes
Coogan et al. (1991b) | Rat | Red blood cells, and white blood cells. Oral and IV injection. Spot samples at 1 hr, 24 hr, and 7 d postexposure. | N
Fébel et al. (2001) | Rat | Oral and intrajejunal injection. Urine, feces, jejunum, liver, portae, hepatica, and cava caudalis. Spot sample data (at 60 min for intrajejunal injection, and 3 d for oral exposure). | Y
Kargacin et al. (1993) | Rat, mouse | Oral and IP injection. Single and repeated exposures. Liver, kidney, spleen, femur, lung, heart, muscle, and blood. Spot sample data at 4 and 8 wk for chronic drinking water, 4 and 14 d for repeated IP injections. Spot 24/72 hr data for single IP exposures. | N
MacKenzie et al. (1959) | Rat | Oral and injection into intestine. Stomach, intestine, blood, liver, kidney, spleen, urine, and feces. Spot samples 1, 7, and 14 d postexposure after single oral dose. Spot sample 4 hr after intestinal injection and stomach tube experiments. | Y
Miyai (1980); Miyai et al. (1980) | Rat, mouse | Inhalation, intratracheal. Lung, plasma, RBC, spleen, kidney, duodenum, testes, urine, and feces. Long-term (30+ d) time-course data. | Y
O’Flaherty and Radike (1991) | Rat | Oral and inhalation. Lung, liver, intestine, kidney, muscle, blood, urine, and feces. Exposure for 40 d, with time-course data over 60 d. | Y
Sayato et al. (1980) | Rat | Oral gavage and IV injection. Blood, brain, skull, thyroid, lung, heart, liver, spleen, pancreas, kidney, adrenal, stomach, intestine, bone, muscle, testis, urine, and feces. 30 d time-course data of feces/urine and body retention. 5 d time-course data for tissues. | Y
Susa et al. (1988) | Mouse | Oral and IP injection. Liver, kidney, spleen, testes, urine and feces. Spot sample 24 hr postexposure. 3 d time-course data for urine and feces. This is a chelation study that included Cr VI-only groups. | N

a Notes (yes/no) if study also collected data for Cr III kinetics.

b Notes (yes/no) whether data from a study were used qualitatively or quantitatively in a published PBPK model.

Table C-24 In vitro and ex vivo Cr(VI) studies primarily focused on pharmacokinetics in the GI tract and blood

Reference | Species | Test system | Notes
Gastric systems
De Flora et al. (1987a) | Human | Gastric juice | Hourly gastric juice samples via nasogastric tube. Cr VI reduction capacity estimated for fed and fasted humans. Circadian effects also observed.
De Flora et al. (1997) | Human | Intestinal bacteria, gastric juice | Reduction and mutagenic activity of Cr VI analyzed at 60 min. Reducing capacities derived for intestine and other tissues (blood, RBC, lung fluids/bacteria, saliva).
De Flora et al. (2016) | Human | Gastric juice | Reduction and mutagenic activity of Cr VI analyzed at 60 min.
Donaldson and Barreras (1966) | Human, rat | Gastric juice; intestinal rings | Binding of Cr VI and Cr III by gastric juice (at low and high pH), and uptake by intestinal rings observed.
Gammelgaard et al. (1999) | Rat | Artificial gastric juice; small intestine | lst-order reduction rate half-life derived; permeability parameters through rat jejunum derived.
Kirman et al. (2013) | Human | Gastric juice (fasted) | 2nd-order reduction kinetics for human gastric juice derived. pH-dependent model derived.
Kirman et al. (2016) | Human | Gastric juice (multiple types) | Revised 2nd-order reduction kinetics and pH model. Analysis of fed, fasted, and proton pump inhibitor (PPI) gastric samples.
Proctor et al. (2012) | Rat, mouse | Gastric juice and contents | 2nd-order reduction kinetics derived. Reduction capacities estimated for both species.
Shrivastava et al. (2003) | Rat | Crypt, mid and upper villus, intestinal loop | Cr VI reduction in various tissue types. Capacity and time needed to reduce Cr VI analyzed.
Skowronski et al. (2001) | N/A | Artificial gastric juice | Oral bioaccessibility study. Examined Cr VI reduction in a simulated soil matrix/gastric juice environment.
Wang et al. (2022) | Human | Artificial gastric juice and tissue | In vitro model of intestinal injury. Examined Cr VI reduction and injury as a function of dose and gastric pH.
Reduction or uptake in red blood cells
Aaseth et al. (1982) | Human | RBC | Reduction rate of Cr VI in RBC and trapping of reduced Cr III observed.
Afolaranmi et al. (2010) | Human | Plasma, RBC, whole blood | Distribution into different blood components (RBC and plasma) observed.
Alexander and Aaseth (1995) | Human, rat | Human RBC, rat liver cells | Cellular uptake and reduction analyzed. Effect of pH and anion carrier inhibitors observed.
Beyersmann et al. (1984) | Human | RBC | RBC permeability and reduction analyzed.
Branca et al. (1989) | Human | Human RBC | Reduction of Cr VI in RBC observed.
Coogan et al. (1991b) | Human, rat | RBC, WBC, whole blood | Uptake kinetics, and distribution in cells examined.
Corbett et al. (1998) | Human | Plasma, blood | Reduction in plasma quantified in fed/fasted individuals.
Devoy et al. (2016) | Human | Plasma, RBC, whole blood | Uptake and retention by RBCs for different Cr VI and Cr III species.
Kortenkamp et al. (1987) | Human | RBC | Cellular uptake rates analyzed.
Richelmi et al. (1984) | Rat | RBC, plasma | Reduction of Cr VI in RBC and plasma observed.
Sakurai et al. (1999) | Rat | Blood | Reduction and fate in blood (focus on pentavalent, Cr V).
Wiegand et al. (1985) | Human, rat | RBC | Uptake into RBC analyzed.

a Notes (yes/no) whether data from a study were used qualitatively or quantitatively in a published PBPK model.

Table C-25 In vitro studies primarily examining distribution and reduction mechanisms

| Human | Rat
Liver | Jannetto et al. (2001); Lewalter and Korallus (1989); Levina et al. (2007); Myers and Myers (1998); Pratt and Myers (1993) | Aiyar et al. (1992); Alexander et al. (1982); Alexander et al. (1986); Arillo et al. (1987); De Flora et al. (1985); Garcia and Jennette (1981); Gruber and Jennette (1978); Gunaratnam and Grant (2001); Mikalsen et al. (1989); Mikalsen et al. (1991); Ohta et al. (1980); Rossi and Wetterhahn (1989); Rossi et al. (1988); Standeven and Wetterhahn (1991a); Ueno et al. (1990); Wiegand and Bolt (1985); Wiegand et al. (1986b)
Lung | Harris et al. (2005); Krawic et al. (2017); Luczak et al. (2016); Levina et al. (2007); Petrilli et al. (1986); Petruzzelli et al. (1989); Wong et al. (2012) | De Flora et al. (1985); Standeven and Wetterhahn (1992); Suzuki (1988a); Suzuki and Fukuda (1990)
RBC | Buttner and Beyersmann (1985); Buttner et al. (1988); Ormos and Mányai (1974); Ormos and Mányai (1977); Ottenwälder et al. (1987); Ottenwaelder et al. (1988); Wiegand et al. (1984b); Wiegand and Ottenwaelder (1985); Wiegand et al. (1986a)
Other | | Arslan et al. (1987) (thymocytes); Berndt (1976) (kidney); Debetto et al. (1988) (thymocytes); Liu et al. (1997) (skin); Mertz et al. (1969) (embryo); Standeven and Wetterhahn (1991a) (kidney)
Miscellaneous systems

Denniston and Uyeki (1987), Ortega et al. (2005), Sehlmeyer et al. (1990), Sognier et al. (1991): Chinese hamster ovary

Dillon et al. (2002): Chinese hamster lung

Kitagawa et al. (1982): Bovine RBCs.

Krepkiv et al. (2003): Rabbit liver metallothionein

Merritt et al. (1984): Rabbit blood

O’Brien et al. (1992): Glutathione and other thiols (not specific to a particular tissue or species).

Wei et al. (2016): HeLa cells and MCF-7 cells.

Wada et al. (1983): Dog liver.

Table C-26 Human biomonitoring and biomarker studies

Reference | Biomarker and industry/exposure notes
Bertram et al. (2014) | Urine/Welding (controlled experiment)
Black et al. (2015) | Urine/House dust (remediation study)
Caglieri et al. (2006); Goldoni et al. (2006); Goldoni et al. (2010) | Exhaled breath, plasma, RBCs, urine/Chrome plating
Cena et al. (2015) | Lung deposition (via deposition sampler)/Welding
Chang et al. (2006) | Whole blood/Residents living near electroplating factories
Coniglio et al. (1990) | Urine/Review
Gargas et al. (1994) | Urine/Human volunteer study of ingested chromite ore processing residue in soil
Goldoni et al. (2008) | Exhaled breath, pulmonary tissues/Lung cancer patients
Kalahasthi et al. (2006) | Plasma/Chrome plating (Cr(VI) and Cr(III) workers)
Lukanova et al. (1996) | Lymphocytes, RBCs, urine/Chrome plating
Mignini et al. (2009); Mignini et al. (2004) | Urine blood/Leather working
Miksche and Lewalter (1995) | RBCs, plasma, urine, whole blood/Review of multiple studies and workshop proceedings containing some original data
Minoia and Cavalleri (1988) | Plasma, RBCs, urine/Dichromate-producing factory (multiple job categories)
Minoia et al. (1983) | Urine/Workers exposed to Cr(VI) and Cr(III)
Muttamara and Leong (2004) | Blood, urine/Chromium alloy factory
Nomiyama et al. (1980) | Urine/Population from geographic areas of known chromium pollution
Ohta and Inui (1992) | Lung tissue (autopsy)/Chromate factory
Pierre et al. (2008) | Urine/Chrome plating
Martin Remy et al. (2021) | Urine/Chrome plating
Santonen et al. (2022) | Urine, RBC, exhaled breath condensate, dermal samples/Multiple industries
Sjogren et al. (1983); Welinder et al. (1983) | Urine/Stainless steel welding
Verdonck et al. (2021); Viegas et al. (2022) | Urine, RBC, blood, exhaled breath condensate/Multiple industries
Verschoor et al. (1988) | Urine/Chrome plating
Zhao et al. (2020) | Urine/Residential exposure

Table C-27 Gastric emptying rates for rats, mice, and humans expressed as half-emptying time (T_1/2_) and transit time (KLSD).

Vehicle indicated in parentheses if known.

T_1/2_ (min) | KLSD^a^ (h^−1^) | Reference
Rat
17 | 2.4 | Kirman et al. (2012)
15 (fed) | 2.77 | GastroPlus defaults
7.5 (fasted) | 5.55 | GastroPlus defaults
77 (liquid/semisolid) | 0.54 | Qualls-Creekmore et al. (2010)
118 (solids) | 0.35 | Enck and Wienbeck (1989)
1.1 fasted (liquid) | 38 | Takashima et al. (2013)
62 fed, 9 fasted^b^ (liquid) | 0.67, 4.6 | Poulakos and Kent (1973)
119–138 (solid) | 0.30–0.35 | Schoonjans et al. (2002)
21–27 (semisolid) | 1.5–2 | Purdon and Bass (1973)
4.95 fasted (liquid) | 8.4 | Kataoka et al. (2012)
16.5 (liquid) | 2.52 | Scarpignato et al. (1984)
Mouse
4.4 | 9.4 | Kirman et al. (2012)
9.6 (fed) | 4.33 | GastroPlus defaults
2.4 (fasted) | 17.3 | GastroPlus defaults
30.6 | 1.36 | Inada et al. (2004)
16–17 fed (semisolid) | 2.60 | Roda et al. (2010)
2 fasted (semisolid) | 20.8 | Roda et al. (2010)
9–11 (liquids) | 3.78–4.62 | Symonds et al. (2002)
158 (solids) | 0.26 | Symonds et al. (2002)
20 (nonnutrient liquid) | 2.08 | Symonds et al. (2008)
36 (nutrient liquid) | 1.16 | Symonds et al. (2008)
91 (solids) | 0.46 | Choi et al. (2007)
30.6 (semisolid) | 1.36 | Osinski et al. (2002)
10 (nonnutrient liquid) | 4.2 | Miyasaka et al. (2004)
90 min (young mice); 58–67 min (old mice); pharmaceuticals | 0.46 (young); 0.62–0.72 (old) | De Smet et al. (2006)
28 (solids, 19–38) | 1.49 (1.09–2.19) | Bennink et al. (2003)
15 (liquids, 11–19) | 2.77 (2.19–3.78) | Bennink et al. (2003)
Human
35 | 1.2 | Kirman et al. (2013)
13 (liquid, fasted) | 3.20 | Mudie et al. (2014)
Fasted; 15.8 (water); 12 (saline); 75 (glucose) | 2.63; 3.47; 0.55 | Mudie et al. (2010) (review article; see citation for further details of individual studies)
Fed; 44 ± 15, 40 ± 13, 32 ± 7, 48 ± 9, 76 ± 6 (liquids); 105 ± 21 (solids) | 0.55–1.30 (liquids); 0.40 (solids) | Mudie et al. (2010) (review article; see citation for further details of individual studies)
30 | 1.39 | ICRP (2002, 2006)
30 (fed) | 1.39 | GastroPlus defaults
7.5 (fasted) | 5.55 | GastroPlus defaults

a KLSD = log_e_(2)/T_1/2_ × 60.

b Poulakos and Kent (1973) values from gastric emptying equation (1-exp(-t/tau), tau = 13 minutes fasted, 89 minutes fed, derived assuming 90% emptying at 30 minutes for the fasted state, 74% emptying at 120 minutes for the fed state).

Time-weighted average daily doses differ from doses presented in the evidence tables of the April 2014 preliminary materials document (U.S. EPA, 2014b) because those values were based on the average of three lifestages (and not weekly/monthly time-course data). Round-off error occurred at the low doses due to lack of significant figures reported in NTP lifestage summary data. Time-weighted average daily doses for mice and rats are presented in Tables C-28 and C-29, respectively. Lifetime average daily internal doses for the rat during the NTP 2-year bioassay (at different data collection times) are presented in Table C-30.

Table C-28 Time-weighted average daily doses in mice for the NTP (2008) 2-year bioassay of sodium dichromate dihydrate.

Doses in mg/kg-day Cr(VI).

Original average daily dose (mg/kg-d) | Time-weighted average daily dose (mg/kg-d) | Percent difference
Female mice
0.38 | 0.302 | 20
1.4 | 1.18 | 15
3.1 | 3.24 | 4
8.7 | 8.89 | 2
Male mice
0.38 | 0.450 | 18
0.91 | 0.914 | 0.4
2.4 | 2.40 | <0.1
5.9 | 5.70 | 3

Table C-29 Time-weighted average daily doses in rats for the NTP (2008) 2-year bioassay of sodium dichromate dihydrate.

Doses in mg/kg-day Cr(VI).

Original average daily dose (mg/kg-d) | Time-weighted average daily dose (mg/kg-d) | Percent difference
Female rats
0.24 | 0.248 | 3
0.94 | 0.961 | 2
2.4 | 2.60 | 8
7 | 7.13 | 2
Male rats
0.21 | 0.200 | 4
0.77 | 0.796 | 1
2.1 | 2.10 | <0.1
5.9 | 6.07 | 3

Table C-30 Time-weighted average daily doses in rats for the NTP (2008) 2-year bioassay of sodium dichromate dihydrate at different time periods.

Doses in mg/kg-day Cr(VI).

Cr(VI) concentration | TWA dose at 2 yr (mg/kg-d) | TWA dose at 1 yr (mg/kg-d) | TWA dose at 90 d (mg/kg-d)
Females
5 | 0.248 | 0.0294 | –
20 | 0.961 | 1.14 | –
60 | 2.60 | 3.01 | –
180 | 7.13 | 8.28 | –
Males
5 | 0.200 | 0.237 | 0.401
20 | 0.796 | 0.938 | 1.58
60 | 2.10 | 2.49 | 4.16
180 | 6.07 | 7.19 | 11.7

TWA BW at 2 yr: 450 g (males) and 260 g (females). TWA BW at 1 yr: 395 g (males) and 215 g (females). No dose-response data for female rats at 1 yr for this assessment.

## C.2 SUPPORTING EVIDENCE FOR SPECIFIC HEALTH EFFECTS

### C.2.1 Respiratory Effects

#### C.2.1.1 Mechanistic studies relevant to noncancer respiratory toxicity

Mechanistic evidence investigating the biological pathways involved in respiratory toxicity following the inhalation of Cr(VI) is summarized in Table C-31. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “inhalation” if they were studies of humans or animals exposed via inhalation or intratracheal instillation and conducted in lung tissues or cells or in cells derived from lung tissues. Studies of systemic toxicity following inhalation exposures are summarized in Appendix C.3.2. A total of 255 potentially relevant respiratory mechanistic studies were identified. A prioritization strategy was used to identify the evidence most informative to chronic human exposures:

- Studies of respiratory organs and tissues from humans with quantified inhalation exposure to Cr(VI)
- Experimental animal (mammalian) studies of respiratory organs and tissues exposed to Cr(VI) via inhalation or intratracheal instillation
- In vitro studies in human primary or immortalized cells derived from respiratory tissues.
- Any outcome measured in lung tissues except for those relevant to genotoxicity (see Appendix C.3.2.2)

Forty-one studies meeting these prioritization criteria were identified; these studies focused primarily on oxidative stress, apoptosis, and cellular toxicity of the lung. Mechanistic evidence relevant to Cr(VI)-induced genotoxicity is reviewed in Appendix C.3.2.2.

Table C-31 Mechanistic studies prioritized for informing potential Cr(VI)-induced respiratory toxicity

System | Exposure^a^ | Results | Comments | Reference
Oxidative stress
Exposed: lead chromate pigment factory workers (n = 22); Referents: office workers from chromate factory (n = 16) | Mean (SD) duration of work among chromate pigment workers = 9.7 (20.5)* yr.; Chromium measured in urine, blood, and air; air sampling for 200 min at flow rate 2–3 L/min; urine and blood measured with flameless atomic absorption spectrophotometer.; Chromium in air ranged from below LOD (0.0005 mg/m^3^ among office workers to 0.5150 mg/m^3^ in high-exposure area of factory (pulverizing process); mean (SD) chromium among exposed group in blood: 6.75 (3.30) μg/L; in urine: 12.97 (16.31) (μg/g creatinine). | In blood and sputum:; No difference in 8-OHdG adducts (in respiratory epithelial and white blood cells) between exposed and control groups, or with duration of employment among exposed groups | Chromium levels in blood (which are a marker of recent exposure) were similar between exposed and control groups; this suggests that exposure misclassification might be contributing to the null effects reported in the study.; The authors also suggest urinary chromium reflects chromium in reduced form, which might not reflect genotoxicity in blood cells.; No adjustment for supplements/vitamins or diet; *SD appears incorrect | Kim et al. (1999)
Rat, Sprague-Dawley | 0.25 mg/kg Na_2_Cr_2_O_7_ (0.09 mg Cr(VI)/kg) per day via intratracheal instillation, 3 d. | ↑ 8-OHdG adducts ([32P] postlabeling) were detected in lung, but not liver.; ↑ DNA-protein crosslinks; ↑ DNA fragmentation | No measure of cytotoxicity | Izzotti et al. (1998)
Rat, Sprague-Dawley, male | 0.18 or 0.9 mg/m^3^ Na_2_CrO_4_ solution mist inhalation, whole-body exposures in 1 m^3^ volumetric inhalation chambers for 1, 2, or 3 wk; Cr levels in blood and urine increased with dose and duration. | ↑ 8-OHdG in lung only at 1 wk (only stat. sig. for 0.18 mg/m^3^); ↓ 8-OHdG repair 1–3 wk | Cr levels confirmed in inhalation chambers with personal air samplers and measured in whole blood and urine.; Indicates Cr(VI) exposure both increases oxidative DNA damage and inhibits repair of these lesions | Maeng et al. (2003)
Rat, Sprague-Dawley, male | 0.063 or 0.630 mg Cr/kg (as K_2_Cr_2_O_7_) via intratracheal instillation, 1×/wk, 4 wk | ↑ 8-OHdG; ↑ NF-κB; ↓ CC16 in club cells | Weekly instillations allow recovery period, which could underestimate the responses, but significant effects were still reported.; Also ↑ relative lung weight, ↑ albumin and total protein level in BALF | Zhao et al. (2014)
Apoptosis
Exposed: Chromium workers diagnosed with lung cancer (n = 67 males); Referent: male controls with lung cancer but without known exposure to chromium (n = 104) | Mean exposure time 16.7 ± 10.0 (SD) yr (range 1–41 yr).; Total and hexavalent Cr measured in soil and air samples taken “in the vicinity of the workplace” using atomic absorption spectrometry.; Mean values of Cr(VI) in air of smelting plants were 0.019–0.03 mg/m^3^. Soil chromium was 137 mg/kg. | In lung cancer tissues (preserved in paraffin blocks):; ↓ survivin protein levels (anti-apoptotic); ↑ p53 protein levels (pro-apoptotic) | The information regarding potential exposure is sparse. Observed differences in the type of lung cancer between exposed and referent could impact results. No information on smoking, which may be important to consider given all participants had lung cancer. | Halasova et al. (2010)
Rat, Sprague-Dawley, male | 0.25 mg/kg Na_2_Cr_2_O_7_ per day via intratracheal instillation, 3 d. | ↑ apoptosis in bronchial epithelium and lung parenchyma; ↑ 13/18 apoptosis-related genes (cDNA array analysis) in lung | Exposures to Cr(VI) alone. TUNEL analysis, used to measure apoptosis, is a sensitive method of detection.; State another lab saw no lung cancer after similar treatment for 30 mo, so predict apoptosis is protective post-genotoxicity | D’Agostini et al. (2002)
Lung cellular responses
Exposed: Electroplaters (n = 42 females); Referent: Jail wardens, frequency matched on age, BMI, alcohol, and smoking (n = 43 females) | Cr(VI) in plasma measured using atomic absorption spectrophotometry.; Total Cr was not different between exposed and referent (means of 0.44 and 0.41 μg/L, respectively). | ↑ cytotoxicity in exfoliated buccal and nasal mucosa | Workers performed bright plating that has lower potential for Cr(VI) exposure, and state that there was good compliance with PPE usage. This might account for the low plasma Cr(VI) levels and similarity between exposed and referent. Co-exposure to cobalt occurred, although levels were not different between exposed and referent.; High prevalence of smoking (frequency matched between exposed and referent), which could affect results. | Wultsch et al. (2017)
Rat, F-344, male | 360 μg/m^3^ K_2_CrO_4_ via inhalation, 5 hr/d, 5 d/wk, 2 or 4 wk. | ↑ total recoverable cells, neutrophils (PMN), and monocytes at 2 and 4 wk in BALF; decline at 4 wk compared with 2 wk; ↓ % PAM in BALF; no change in total PAM levels; No changes in cell viability (80%–90%) among exposure groups | Moderately informative: shorter exposure period but results generally support similar findings from chronic duration studies from same group.; Ex vivo PAMs (exposed in vivo to K_2_CrO_4_):; - Spontaneous: ↑ H_2_O_2,_ no changes in superoxide anion; - LPS-inducible: ↑ NO, ↓ IL-1 and TNFα, ↑ IL-6 | Cohen et al. (1998)
Rat, Long-Evans hooded, male | 2 μg CaCrO_4_ (insoluble) or 2 μg CrO_3_ (soluble) via intratracheal instillation, 9 hr. | In vivo exposure: no effect on cell viability; In vitro exposure: ↓ viability | Less informative: short exposure period; trypan blue dye exclusion is a less sensitive measure to determine cell viability | Galvin and Oberg (1984)
Rat, Sprague-Dawley, male and female | 0.01, 0.05, 0.25 mg/kg Na_2_Cr_2_O_7_-2H_2_O, 5×/wk, or 0.05, 0.25, 1.25 mg/kg, 1×/wk via intratracheal instillation, 30 wk. | Tumors that appeared to arise from tissues with cellular inflammatory foci involving alveolar macrophages, proliferation of bronchiolar epithelium or alveolar type II cells, and chronic inflammatory thickening of alveolar septa. The other main type of nontumor lesion was severe damage to the bronchioloalveolar region with alveolar atelectasis and subsequent confluent fibrosis. | | Steinhoff et al. (1986)
Rat, Sprague-Dawley, male | 0, 0.063 and 0.630 mg Cr/kg (as K_2_Cr_2_O_7_) via intratracheal instillation, 1×/, 4 wk | ↑ relative lung weight; ↑ albumin and total protein level in BALF; ↑ NF-κB; ↓ CC16 in club cells | More informative: weekly instillations allow recovery period, which could underestimate the responses, but significant effects were still reported.; Also ↑ 8-OHdG | Zhao et al. (2014)
In vitro studies of oxidative stress, cellular toxicity, and death in primary and immortalized human lung cells
HLF fetal human lung fibroblasts; L-41 human epithelial-like cells | 1, 2, 5, 10, 15, 20, 25, and 30 μM K_2_Cr_2_O_7_, 2, 24 or 48 h | ↑ cytotoxicity (MTT assay), dose- and duration dependent (significant ≥20 μM); cytotoxicity recovered ≤5 μM after 24 hr; ↑ ROS(DCFH-DA)at 2 hr; ↑ antioxidant enzymes (glutathione peroxidase, glutathione reductase, catalase) 1–5 μM | Oxidative stress and antioxidant enzymes induced at mildly toxic μM concentrations | Asatiani et al. (2010); Asatiani et al. (2011)
H460 human lung epithelial cells | 10–50 μM Na_2_Cr_2_O_7_, 12 hr | ↑ ROS; ↑ apoptosis; abrogated by antioxidants MnTBAP, catalase, DPI, or ROT, in cells transfected with antioxidant enzymes SOD or GPx, or by specific caspase inhibitors.; ↓ Bcl-2; abrogated by MnTBAP | Cr(VI) induces apoptosis by downregulating Bcl-2 via superoxide anion-mediated ubiquitin-proteasomal degradation and mitochondrial caspase-9 activation | Azad et al. (2008)
BEAS-2B human bronchial epithelial cells | 0.3 (nontoxic) or 1.8 (toxic) μM Cr(VI), 48 hr | Cytotoxic signaling pathways: glycolysis regulation (GSK3beta, p70S6K), oxidative stress and inflammation (JNK, MTF-1), and protein degradation (UBC) | | Bruno et al. (2016)
A549 human alveolar epithelial adenocarcinoma cells; BEAS-2B human bronchial epithelial cells | 0.5, 1, and 2 μM Cr(VI) (compound not reported), 3, 8, or 24 hr | In BEAS-2B:; ↑ cytotoxicity (≥1 μM; MTT); ↓ glutathione (3 hr only); ↑ lipid peroxidation (TBARS); ↑ heme oxygenase-1 (HO-1); A549:; ↑ lipid peroxidation (TBARS) | BEAS-2B cell line more sensitive to Cr(VI) effects than A549 cell line; polymorphisms for GST genes might be responsible for differing cellular responses to Cr(VI) | Caglieri et al. (2008)
HLF human lung fibroblasts (LL-24 cell line) | 3, 6, and 9 μM Na_2_CrO_4_, 24 hr | ↑ cytotoxicity, duration and dose dependent (stat. sig. ≥6 μM); ↑ apoptosis; ↑ p53 (4–6 fold) | Pretreatment with 1 mM ascorbate or 20 μM tocopherol had no ameliorative effects; Also ↑ Cr-DNA adducts | Carlisle et al. (2000a)
A549 (human alveolar epithelial adenocarcinoma) and BEAS2B human bronchial epithelial cells | 0.1, 0.5, 1.0 and 10 μM Na_2_CrO_4_, 0.5, 1, and 4 hr | ↑ apoptosis at 10 μM (caspase-3 activity and morphology) | Oxidative role in DNA damage decreased with time at lower Cr(VI) concentrations and increased with time at higher concentrations; A549 more sensitive than BEAS2B; Also ↑ oxidative DNA damage (Fpg-modified comet assay) | Cavallo et al. (2010)
BEAS-2B human bronchial epithelial cells | 1 μM Cr(VI), 48 hr | ↑ glycolysis; ↓ respiration; ↓ protein levels of β-F1-ATPase; ↑ GAPDH | Cr(VI) caused shift to fermentative metabolism | Cerveira et al. (2014)
Human non-small cell lung carcinoma CL3 cells | 10–80 μM K_2_Cr_2_O_7_, 1–12 hr | ↑ JNK; ↑ MAPK11-14 (P38); ↑ MAPK3, MAPK1 (ERK1/2) | Activation increased with dose and duration.; Use of multiple oxidants and antioxidants shows activation of these redox-initiated pathways do not clearly correlate with Cr(VI)-induced cytotoxicity | Chuang et al. (2000)
BEAS-2B human bronchial epithelial cells transformed by chronic Cr(VI) exposure | Na_2_Cr_2_O_7_ | In Cr(VI)-transformed cells:; ↑ metabolic adaptation and antioxidant defense, ATP production and mitochondrial proton leak via SIRT3; ↑ mitophagy proteins Pink1 and PRKN (Parkin), though mitophagy was suppressed | SIRT3 upregulation by Cr(VI) suppresses mitophagy; knockdown of SIRT3 suppressed cell proliferation; NRF2 constitutively activated in Cr(VI)-transformed cells | Clementino et al. (2019)
BEAS-2B human bronchial epithelial cells | 5–20 μM Na_2_Cr_2_O_7_ | ↑ NOTCH1 (Notchl); ↑ CDKN1A (P21); ↓ FBP1 | FBP1, involved in gluconeogenesis, is lost in Cr(VI)-transformed cells; Reintroduction of FBP1 caused ↑ROS and ↑apoptosis | Dai et al. (2017a)
LL 24 human lung cells and A549 human lung adenocarcinoma cells | 5–200 μM Cr(VI) | ↑ heme oxygenase gene (only in LL 24 cells); No effect on catalase, GST, glutathione reductase, Cu/Zn- and Mn-SODs, GPx, NAD(P)H:quinone oxidoreductase, or IL-8 gene expression | RT-PCR and northern blot gene (RNA) expression analyses; Authors conclude heme oxygenase is responsible for Cr(VI)-induced stress responses and not intracellular increases in glutathione and ROS | Dubrovskaya and Wetterhahn (1998)
BEAS-2B human bronchial epithelial cells; MOLT-4 lymphoblastic leukemia cell line | 0.5, 3, 6, 9, and 200 μM K_2_Cr_2_O_7_, 4, 12, or 24 hr | ↑ apoptosis (PI; TUNEL flow), dose and time dependent; ↑ p53 at 0.5 μM (12 hr) and 3 μM (4 hr) in MOLT-4 but not BEAS-2B cells; Inhibition of caspase-3, -8 and -9 did not reduce apoptosis | Cr(VI) induces apoptosis that could involve p53 in MOLT-4 cells but not in BEAS-2B; apoptosis did not involve caspases 3, 8, or 9 in these cells; Altered p53 function in MOLT-4 and BEAS-2B cell lines limits ability to interpret results for normal p53 function | Gambelunghe et al. (2006)
A549 human alveolar epithelial adenocarcinoma cells | 0.2 μM K_2_Cr_2_O, 6, 12, or 24 hr | ↑ endoplasmic reticulum (ER) stress via ↑ GRP78 and p-PERK is associated with ↑ apoptosis and autophagy; ↓ mitochondrial membrane potential (MMP) at 6–12 hr but not 24 hr | Inhibiting ER stress (4PBA) reduced apoptosis and autophagy.; Suppressing apoptosis (Z-VAD-FMK) also suppressed autophagy.; Inhibiting autophagy (3-MA) increased apoptosis; Authors surmise Cr(VI)-induced autophagy rescues ↓ MMP at 24 hr via phagocytosing damaged mitochondria and then inhibiting apoptosis | Ge et al. (2019)
A549 human alveolar epithelial adenocarcinoma cells | 10–500 μM Na_2_Cr_2_O_7_, 1 or 16 hr | ↑ 8-OHdG; ↓ OGG1 mRNA, dose dependent (RT-PCR and RNase protection assay); not affected by adding H_2_O_2_; No effect on hAPE or GAPDH | Authors conclude Cr(VI)-induced oxidative DNA damage could be due partly to a reduced capacity to repair endogenous and Cr(VI)-induced 8-OHdG lesions; Also ↑ DNA strand breaks, dose dependent (comet assay) that were 10x higher with FAPY | Hodges et al. (2001); Hodges and Chipman (2002)
A549 human alveolar epithelial adenocarcinoma cells | 12.5–800 μM Cr(VI) | ↑ ROS and NF-κB, dose dependent; Effects abrogated by catalase, SOD, or D-mannitol; No change in 8-OHdG levels or hogg1 expression | Possible that ≤800 μM doses of Cr(VI) are sufficient to induce ROS and NF-κB but too low to induce oxidative DNA lesions | Kim et al. (2003)
A549 human alveolar epithelial adenocarcinoma cells | 5–80 μM Na_2_Cr_2_O_7_, 2 h | ↑ cytotoxicity >5 μM, dose dependent; Cr(VI) + 1 mM ascorbate; ↑ ROS; Cr(VI) + glutathione; ↓ ROS | Ascorbate (max intracellular 80 μM) might promote Cr(VI)-induced oxidative stress by reducing intracellular Cr(VI) and stabilizing Cr(VI) and Cr(IV) | Martin et al. (2006)
Primary human bronchial epithelial cells; BEAS-2B human bronchial epithelial cells | 25 and 50 μM Na_2_CrO_4_, 3 or 6 h | Irreversible inhibition of thioredoxin reductase (TrxR); Oxidation of protein thiols thioredoxins (Trx) and peroxiredoxins (Prx); scavenging peroxynitrite (MnTBAP) or adding ascorbate did not abrogate these effects; Inhibition of aconitase, electron transport complexes I and II | Cr(VI) oxidizes and inhibits mitochondrial and cellular thioredoxins and peroxiredoxins involved in cell survival and redox signaling, leading to increased sensitivity to ROS damage and decreased survival | (Myers et al., 2010; Myers et al., 2011);(Myers et al., 2008; Myers and Myers, 2009)
A549 human alveolar epithelial adenocarcinoma cells | 10 μM Cr(VI) | ↑ ROS and JNK activation at subcytotoxic levels; ↑ Src family kinases (Fyn, Lck) at levels that did not induce ROS | | O’Hara et al. (2003)
BEAS-2B human bronchial epithelial cells; SAECs (human small airway epithelial cells) | 0.2, 2.0, 20, and 200 μM K_2_Cr_2_O_7_, 1, 2, 6, or 48 h | ↑ cytotoxicity (MTT assay) at 0.2 μM (20%) in BEAS-2B, 20 μM in SAEC, dose dependent; In SAECs:; ↑ cellular phosphoprotein; ↑ IL-6, IL-8 (precytotoxic, at 0.2 and 2.0 μM, respectively); Null for TNF-α | Cytotoxicity associated with inflammation and immune response via protein phosphorylation and cytokine signaling | Pascal and Tessier (2004)
A549 human alveolar epithelial adenocarcinoma cells | 0.13, 0.67, 3.38, 16.9, and 84.57 μM CrO_3_ or K_2_Cr_2_O_7_ | ↑ cytotoxicity ≥3.38 μM (colony formation assay), dose dependent | Cytotoxicity induced at μM concentrations | Popper et al. (1993)
Primary human lung IMR90 fibroblasts; H460 human lung epithelial cells | 0.2–8 μM K_2_CrO_4_, 3 hr | ↑ DNA DSB with ascorbate caused by aberrant mismatch repair, dose-dependent; ↑ cytotoxicity and apoptosis with ascorbate; effects reversed by suppressing DNA mismatch repair but p53 status had no effect; ↑↑ cytotoxicity and cell cycle delay in cells deficient in oxidative DNA damage repair (XRCC1 knockdown); effects reversed by ascorbate | By restoring intracellular ascorbate to physiological levels via DHA (max intracellular 0.9 mM), it was shown ascorbate can suppress Cr(VI)-induced oxidative damage but promotes Cr-DNA lesions that are either repaired by mismatch repair, independently of p53, or lead to cytotoxicity and apoptosis; Chromosomal aberrations not affected by XRCC1 status | Reynolds and Zhitkovich (2007); Reynolds et al. (2012); Reynolds et al. (2007)
A549 human alveolar epithelial adenocarcinoma cells | 1–20 μM Na_2_Cr_2_O_7_, 4 or 12 hr | ↑ cytotoxicity with dose (stat. sig. at 20 μM) at 4 hr; ↓ specific activity and level of urokinase-type plasminogen activator (uPA) activity; ↑ uPA receptor protein | Cr(VI) inhalation leads to a net loss of urokinase-type plasminogen activator activity that has been shown to promote pulmonary fibrosis | Shumilla and Barchowsky (1999)
A549 human alveolar epithelial adenocarcinoma cells | 0.05, 0.1, 0.2, 0.4, 0.8, 1.6, 3.2, 6.4, and 12.8 μM K_2_Cr_2_O_7_, 24 hr | ↑ cell proliferation ≤0.2 μM (A549 cells); ↑ cytotoxicity ≥3.2 μM; ↑ autophagosomes; this effect was blocked by silencing HMGA2; ↑ expression of LC3II, Atg12-Atg5, Atg4, Atg10, HMGA1 and HMGA2 proteins; ↓ expression of p62 | Cr(VI)-induced autophagy is correlated with transcription factor HMGA2 expressed in lung cancer patients | Yang et al. (2017)

BALF: bronchoalveolar lavage fluid.

ICP-AES: inductively coupled argon plasma atomic emission spectroscopy.

MMA-SS: manual metal arc-stainless steel.

PAM: pulmonary alveolar macrophages.

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.2.2 Gastrointestinal Effects

#### C.2.2.1 Apical outcomes relevant to toxicity of the gastrointestinal tract

The results relevant to GI tract toxicity from the four high confidence animal studies synthesized in Section 3.2.2.2 of the toxicological review (2011b; Thompson et al., 2012c; NTP, 2007f, 2008) are summarized in Table C-32. In addition to these four studies are other reports that continued to evaluate the same tissues from these studies, and a fifth study (Thompson et al., 2015b) that was evaluated only for genotoxicity endpoints but also reported evidence of hyperplasia and Cr accumulation in GI tissues following drinking water exposures.

Table C-32 Experimental animal studies providing apical evidence of toxic effects of ingested Cr(VI) in the GI tract

System | Exposure^a^ | Results | Reference
Mouse (B6C3F1), male and female | 0, 22, 44, 87, 174, 349 mg/L Cr(VI); 0, 3.1, 5.3, 9.1, 15.7, 27.9 mg/kg-d Cr(VI); 90 d | Diffuse epithelial hyperplasia of the duodenum (≥3.1 mg Cr(VI)/kg-d); Duodenal villi short, thick, and blunted, with cytoplasmic vacuolization in the epithelial cells lining the villi tips (all doses, not quantitatively measured) | NTP (2007f)
Mouse, BALB/c, C57BL/6, and B6C3F1, male (strain comparison study) | 0, 22, 44, 87 mg/L Cr(VI); 0, 2.8, 5.2, 8.7 mg/kg-d Cr(VI); 90 d | Diffuse epithelial hyperplasia of the duodenum (≥2.8 mg Cr(VI)/kg-d) | NTP (2007f)
Rat, F344/N, male and female | 0, 22, 44, 87, 174, 349 mg/L Cr(VI); 0, 1.7, 3.5, 5.9, 11.2, 20.9 mg/kg-d Cr(VI); 90 d | Epithelial hyperplasia, squamous metaplasia, and ulcers in the glandular stomach (20.9 mg/kg-d) | NTP (2007f)
Rat (F344/N), male | 0, 5, 20, 60, or 180 mg/L Cr(VI); 0.200, 0.760, 2.10, 6.07 mg/kg-d Cr(VI); 2 yr | No observed GI hyperplasia/metaplasia or stomach ulcers; No salivary gland atrophy | NTP (2008)
Rat (F344/N), female | 0, 5, 20, 60, or 180 mg/L Cr(VI); 0.248, 0.961, 2.60, 7.13 mg/kg-d Cr(VI); 2 yr | No observed GI hyperplasia/metaplasia or stomach ulcers; Mild salivary gland atrophy at highest dose (≥7.13 mg Cr(VI)/kg-d) | NTP (2008)
Mouse (B6C3F1), male | 0, 5, 10, 30, or 90 mg/L Cr(VI); 0.450, 0.914, 2.40, or 5.70 mg/kg-d Cr(VI); 2 yr | Diffuse epithelial hyperplasia of the duodenum (≥0.45 mg Cr(VI)/kg-d); Focal epithelial hyperplasia ≥2.40 mg/kg-d, not statistically significant; Short, broad, and blunt duodenal villi (no overt damage, necrosis, or degeneration indicative of atrophy) | NTP (2008)
Mouse, (B6C3F1), female | 0, 5, 20, 60, or 180 mg/L Cr(VI); 0.302, 1.18, 3.24, or 8.89 mg/kg-d Cr(VI); 2 yr | Diffuse epithelial hyperplasia of the duodenum (≥0.3 mg Cr(VI)/kg-d) and jejunum (8.89 mg/kg-d); Focal epithelial hyperplasia ≥3.24 mg/kg-d, not statistically significant; Short, broad, and blunt duodenal villi (no overt damage, necrosis, or degeneration indicative of atrophy) | NTP (2008)
Mouse, B6C3F1 female; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI); 7 d (n = 5) or 90 d (n = 10) | 7-d:; Duodenal hyperplasia (no statistically significant change), villous atrophy (no statistically significant change), and cytoplasmic vacuolization (statistically significant at 31.1 mg/kg), with no change in crypt apoptosis indices, mitotic activity, or increases in karyorrhectic nuclei in crypts; 90-d:; Diffuse epithelial hyperplasia of the small intestine (≥11.6 mg Cr(VI)/kg-d); Villous atrophy in duodenum and jejunum (31.1 mg/kg-d); Apoptosis in duodenal villi (31.1 mg/kg-d); Cytoplasmic vacuolization in duodenum and jejunum (≥4.6 mg Cr(VI)/kg-d | Thompson et al. (2011b)
Rat, Fischer 344/N female; Oral, drinking water | 0, 0.1, 1.4, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.015, 0.21, 2.9, 7.2, 20.5 mg/kg-d Cr(VI); 7 d (n = 5) or 90 d (n = 10) | Diffuse epithelial hyperplasia of the small intestine (≥7.2 mg Cr(VI)/kg-d), villous cytotoxicity (≥7.2 mg Cr(VI)/kg-d); Apoptosis in duodenal villi (≥7.2 mg Cr(VI)/kg-d) (no atrophy or vacuolization); 7 d: No statistically significant changes in GSH/GSSG in oral mucosa or small intestine except in jejunum at 20.5 mg/kg-d and at 0.015 mg/kg-d in the oral mucosa. Note: sample size is 5 for 7 d data.; 90 d: ↓ GSH/GSSG in oral mucosa and jejunum (≥2.9 mg/kg-d) and in plasma (≥7.2 mg/kg-d), dose-dependent, statistically significant. No changes in duodenum, or signs of lipid peroxidation (8-isoprostane) in any tissues. | Thompson et al. (2012c)
Mouse, B6C3F1; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI); 7 and 90 d | In scraped duodenal epithelium:; ↑ crypt enterocyte proliferation, dose dependent; ↑ villus cytotoxicity (disruption of cellular arrangement, desquamation, nuclear atypia, blunting); ↑ crypt enterocyte proliferation, dose dependent; No effect on mitotic/apoptotic indices in crypt compartment; 7 d:; ↑ aberrant nuclei at villi tips but not in crypts (≥11.6 mg/kg-d); 90 d:; ↑ aberrant nuclei at villi tips but not in crypts (≥4.6 mg/kg-d) | O’Brien et al. (2013); Continued analysis of tissues from Thompson et al. (2011b)
Mouse (B6C3F1) and rat (F344), female; Oral, drinking water | 0 and 180 mg/L Cr(VI); 0 and 31.1 mg/kg-d Cr(VI); 90 d | In duodenal villi and crypts:; X-ray fluorescence (spectro)microscopy (μ-XRF) was used to image the Cr content in the villus and crypt regions of duodena. Cr(VI) was detected in crypts, slightly above detection limits, and was >30× higher in villi.; Villous blunting and crypt hyperplasia in the duodenum (lengthening of the crypt compartment by ~2-fold); 1.5-fold increase in the number of crypt enterocytes; No aberrant foci indicative of transformation | Thompson et al. (2015a); Continued analysis of tissues from Thompson et al. (2011b)
Mouse, B6C3F1; Oral, drinking water | 0, 1.4, 21, and 180 mg/L Cr(VI); 0, 0.32, 4.6, and 31.1 mg/kg-d Cr(VI); 7 d | 21 and 180 mg/L Cr(VI) significantly increased the number of crypt enterocytes; Synchrotron-based X-ray fluorescence (XRF) microscopy revealed the presence of strong Cr fluorescence in duodenal villi, but negligible Cr fluorescence in the crypt compartment; No effect on aberrant villous foci, and X-ray fluorescence detection of Cr(VI) | Thompson et al. (2015b)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

#### C.2.2.2 Mechanistic endpoints relevant to toxicity of the gastrointestinal tract

Studies examining mechanistic endpoints relevant to interpretations of toxic effects in the GI tract are summarized in Table C-33. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “GI” if conducted in GI tissues or cells. Only studies conducted in vivo in animals or in vitro in human cells from the GI tract are prioritized for consideration here:

- Studies of gastrointestinal organs and tissues from humans with quantified exposure to Cr(VI)
- Experimental animal studies of gastrointestinal tissues (except liver; these studies are summarized in Appendix C.2.3) using quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation exposures
- In vitro studies in human primary or immortalized cells derived from gastrointestinal tissues
- Mechanistic endpoints relevant to interpretations of gastrointestinal toxicity in humans except for genotoxicity studies (see Appendix C.3.2.2) (apical outcomes synthesized for noncancer hazard identification have been summarized above in Appendix C.2.2.1)

Ten studies in experimental animals and four studies in GI-derived cells in vitro were identified. No human exposure studies of toxicity of the GI tract were identified (studies in exposed workers reporting genotoxic endpoints in buccal cells are summarized in Appendix C.3.2.2).

Table C-33 Supporting mechanistic studies prioritized for informing Cr(VI)-induced GI tract toxicity

System | Exposure^a^ | Results | Reference
Mouse, B6C3F1 female; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI); 7 d (n = 5) or 90 d (n = 10) | 7 d: No change in crypt apoptosis indices, mitotic activity, or increases in karyorrhectic nuclei in crypts; ↓ GSH/GSSG in oral (≥11.6 mg/kg-d) and duodenal (≥4.6 mg/kg-d) epithelium; no change in plasma. Note: sample size is only 5 for the 7 d group, and some observed changes occurred at slightly lower doses but were not statistically significant.; 90-d:; ↓ GSH/GSSG in duodenum and jejunum (≥1.1 mg/kg-d) and in plasma (≥11.6 mg/kg-d); No statistically significant increases in protein carbonyls or 8-OHdG levels in any tissues; Some altered cytokines and chemokines | Thompson et al. (2011b)
Rat, Fischer 344/N female; Oral, drinking water | 0, 0.1, 1.4, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.015, 0.21, 2.9, 7.2, 20.5 mg/kg-d Cr(VI); 7 d (n = 5) or 90 d (n = 10) | 7 d: No statistically significant changes in GSH/GSSG in oral mucosa or small intestine except in jejunum at 20.5 mg/kg-d and at 0.015 mg/kg-d in the oral mucosa. Note: sample size is 5 for 7 d data.; 90 d: ↓ GSH/GSSG in oral mucosa and jejunum (≥2.9 mg/kg-d) and in plasma (≥7.2 mg/kg-d), dose dependent, statistically significant. No changes in duodenum, or signs of lipid peroxidation (8-isoprostane) in any tissues. | Thompson et al. (2012c)
Mouse, B6C3F1; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI); 7 and 90 d | In scraped duodenal epithelium:; No effect on mitotic/apoptotic indices in crypt compartment; 7 d:; ↑ aberrant nuclei at villi tips but not in crypts (≥11.6 mg/kg-d); 90 d:; ↑ aberrant nuclei at villi tips but not in crypts (≥4.6 mg/kg-d) | O’Brien et al. (2013); Continued analysis of tissues from Thompson et al. (2011b)
F344 rats and B6C3F1 mice; Oral, drinking water | 0, 0.1, 1.4, 4.9 (mice only), 20.9, 59.3, and 181 mg/L Cr(VI), 90; 0, 0.015, 0.21, 2.9, 7.2, 20.5 mg/kg-d Cr(VI) (rats); 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI) (mice) | Dose-dependent decreases in Fe levels in the duodenum, liver, serum, and bone marrow; Considered in hematological effects, not in GI effects synthesis. This assessment determined that evidence indicates Cr(VI) is likely to cause hematological effects based on iron-deficient anemia-like observations in rodents (see Section 3.2.5 of the toxicological review). Such observations were made in some of the studies cited in this table [including (NTP, 2007f, 2008)]. This table does not list the observed hematological effects or effects related to iron homeostasis. See Section 3.2.5 of the toxicological review for a synthesis of hematological effects, or click the HAWC link (https://hawc.epa.gov/summary/data-pivot/assessment/499/CrVI-Animal-Tox-Hematology-Effects-Erythrocytes/) for a summary of selected datasets. | Suh et al. (2014); Continued analysis of tissues from Thompson et al. (2011b) and Thompson et al. (2012c)
Mouse, SKH-1 hairless, female; Oral, drinking water | 0, 5, and 20 mg/L Cr(VI) 1.20 and 4.82 mg Cr(VI)/kg-d; 9 mo | No effect on oxidative 8-OHdG adducts in forestomach, glandular stomach, duodenal cells, lung, or skin.; No measure of cytotoxicity; No changes in body weight | De Flora et al. (2008)
Mouse, C57BL/6J; Oral, drinking water | 0, 0.019, 0.19, 1.9 mg/L Cr(VI); 150 d; 2 animals per dose group | In proximal and distal sections of GI tract:; Histopathology: no effects on villous atrophy/blunting or inflammation; slight enterocyte hypertrophy and crypt hyperplasia; Immunohistochemistry: no effect on Ki67 | Sánchez-Martin et al. (2015)
Rat, Wistar Oral, drinking water | 0, 87, 174, 262, 349, 436 mg/L Cr(VI); 0, 1.7, 3.5, 5.2, 7.0, 8.7 mg/kg-d; 60 d | [underlined: Stomach]:; ↓ p53 protein (≥87 mg/L) and mRNA (≥174 mg/L); ↑ c-Myc protein and mRNA (≥174 mg/L); ↑ galectin-1 protein (≥174 mg/L) and mRNA (≥87 mg/L); ↓ RKIP protein and mRNA (≥262 mg/L); ↓ Rho-GDIα protein and mRNA (≥262 mg/L); [underlined: Colon]:; ↓ p53 protein and mRNA (≥262 mg/L); ↑ c-Myc protein (≥262 mg/L) and mRNA (≥87 mg/L); ↑ galectin-1 protein (≥349 mg/L) and mRNA (≥174 mg/L); ↓ RKIP protein (≥436 mg/L) and mRNA (≥349 mg/L); ↓ Rho-GDIα protein (≥262 mg/L) and mRNA (≥349 mg/L) | Tsao et al. (2011)
Rat, Sprague-Dawley male; Intragastric injection | 1.77 mmol/kg Cr(VI); bile sampling every 40 min | Alpha-(4-pyridyl 1-oxide)-N-tert-butylnitrone (POBN) carbon-centered radical adduct in bile of rats exposed to Cr(VI) | Kadiiska et al. (1998)
Rat; Oral gavage | 530 mg/kg-d Cr(VI), 3 d; 106 mg/kg-d Cr(VI), 30 d; [underlined: Note]: The administered gavage potassium dichromate doses (1,500 mg/kg and 300 mg/kg) are higher than the LD_50_ for rats listed in MSDS (130 mg/kg) | Intestinal epithelial cells, 3 d exposure:; ↓ glucose-6-phosphate dehydrogenase, glutathione peroxidase, glutathione reductase, glutathione-S-transferase, superoxide dismutase and catalase; ↓ glutathione and total thiols; ↑ lipid peroxidation; Intestinal epithelial cells, 30 d exposure:; ↑ superoxide dismutase, glutathione peroxidase; Null glucose-6-phosphate dehydrogenase, glutathione reductase and catalase; ↓ glutathione-S-transferase | Sengupta et al. (1990)
Rat, Wistar, female; i.p. injection | 8.8 mg/kg Cr(VI); Single dose, 48 hr | Type 2 cystatins were induced in kidneys and submandibular acini salivary glands. Not detected in parotid or sublingual glands, or in trachea, lung, stomach, small intestine, large intestine, spleen, liver, or pancreas. | Cohen et al. (1993)
In vitro human primary and immortalized GI cells or gastric fluid
Caco-2 human colorectal adenocarcinoma cells | 0.1, 0.3, 1, 3, 10, 30, 100 μM Cr(VI) | Increase in 8-OHdG at nontoxic and cytotoxic concentrations (decreased cell counts interpreted by authors as cytotoxicity may also be caused by DNA damage-induced growth arrest); No change in p53, annexin-V (apoptosis markers), LC3B (autophagy marker); Translocation of ATF6 to nucleus (ER stress response marker); Caco-2 cell line is unstable, making interpretation of results difficult | Thompson et al. (2012a)
Human wildtype HCT116 colon cancer cells | 30 μM Cr(VI) (formulation and compound uncertain) | Upregulated p53, p21CIP1/WAF1, ATM, DNA-PK, ATR, AKT and p38 (upstream p53 kinases); ↑ apoptosis involves DNA-PK-mediated p53 activation and increased PUMA concurrent with loss of p21; Note: chemical formulation preparation information not provided. The only information given is the chemical was 30 μM Cr(VI) and it was “a gift from Professor Naresh Dalal, Department of Chemistry, Florida State University.” The true dose is therefore unclear (it is possible it is 1/3 this value if the concentration is in units of the parent chromate compound) | Hill et al. (2008b); Hill et al. (2008a)
Human gastric cancer SGC-7901 cells | 3.53 μM Cr(VI) | Oxidative stress, apoptosis and necrosis all increased when the Unconventional prefoldin RPB5 Interacting protein (URI) is knocked down | Luo et al. (2016)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.2.3 Hepatic Effects

#### C.2.3.1 Mechanistic studies relevant to hepatic toxicity

A large body of mechanistic information exists (125 studies) to inform the potential hepatotoxicity of Cr(VI). Therefore, studies more informative for chronic human exposure were prioritized:

- Studies of the liver or liver enzymes from humans with quantified exposure to Cr(VI)
- Experimental animal studies of the liver or liver enzymes using quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation exposure to Cr(VI)
- In vitro studies in human primary or immortalized cells derived from liver.
- Mechanistic endpoints relevant to interpretations of hepatic health effects in humans, including genotoxicity tests in liver tissues.

This prioritization strategy identified 49 relevant studies. These include mammalian studies of the liver or liver enzymes that focused on exposure routes more relevant to humans (oral drinking water, gavage, and diet; inhalation) and repeat dose studies of longer duration (≥28 days). Shorter duration studies, however, also provided some supporting information, and in vitro studies in human liver primary cells or cell lines provided insight into biological plausibility and human relevance of the observed mechanisms. These studies, summarized in Table C-34, primarily reported evidence of Cr(VI)-induced oxidative and endoplasmic reticulum stress, mitochondrial dysfunction, inflammation, apoptosis, DNA damage, and cell proliferation.

Table C-34 Mechanistic studies prioritized for informing potential Cr(VI)-induced hepatic toxicity

System | Route | Exposure^a^ | Results | Comments | Reference
Oxidative and endoplasmic reticulum stress
Mouse, ICR male | Oral feed | 1 and 4 mg/kg/K_2_Cr_2_O_7_-d, 36-d repeat dose; Confirmation by detection of ↑ Cr content in liver | ↑ hepatic lipid peroxidation and MDA; ↑ GSH levels; ↑ CAT and GPx activity and mRNA; ↑ Ho-1, Atf6, CHOP gene expression | | Jin et al. (2014)
Rat, Wistar male | Oral gavage | 30 mg/kg/K_2_Cr_2_O_7_-d, 28-d repeat dose | ↑ hepatic lipid peroxidation; ↓ SOD, CAT, and GST activity; ↑ Atf1 (MAPK stress response pathway) | | Navya et al. (2017)
Mouse, C57BL/J5, male and female | Oral drinking water | 55–5500 μg/L Na_2_Cr_2_O_7_, 5 mo, repeat dose; 2 animals per dose group | ↑ GCLC (glutamyl-cysteine ligase catalytic subunit); Null NRF2 (NF-E2-related factor 2) | ↑ GCLC but the mRNA expression was down; For this study, n = 2 males and 2 females | Sánchez-Martín et al. (2015)
Rat, Sprague-Dawley, female | Oral gavage | 2.5 and 10 mg/kg-d Na_2_Cr_2_O_7_; 30, 60, 90, and 120 d | ↑ hepatic mitochondrial and microsome peroxidation with concurrent excretion of lipid metabolites MDA, FA, ACT, and ACON | (n) not given, concerns with results interpretation; 2002:; 4 animals/group | (Bagchi et al., 1995a; 1997b; 2002b), Stohs et al. (2001)
Rat, Sprague-Dawley, female | Oral gavage | 25 mg/kg Na_2_Cr_2_O_7_ (reported as 0.5 LD_50_), 48 hr | ↑ hepatic mitochondrial and microsome peroxidation with concurrent excretion of lipid metabolites | 1995b n = 4–6 animals per group | Bagchi et al. (1995b)
Mouse, C57BL/6NTac and N12 p53-deficient C57BL/6TSG-p53, female | Oral gavage | 2000&2002: 0.50 LD_50_, 0.10 LD_50_, 0.01 LD_50_.; 2001: 0.50 LD_50_ reported as 95 mg/kg; Na_2_Cr_2_O_7_ after 24 hr; 24 hr, 48 hr, and time course up to 96 hr, respectively | ↑ hepatic cytochrome C (reported as SOA production); ↑ hepatic lipid peroxidation | Dosing and (n) not given (2000 and 2002) | (Bagchi et al., 2000a; Bagchi et al., 2001); Bagchi et al. (2002a)
Rat, albino | Oral gavage | 50 mg/kg-d; K_2_Cr_2_O_7_, 20 d repeat dose | ↑ liver triglycerides and phospholipids | Uninformative factors expected to decrease confidence in mechanistic reporting | Kumar and Rana (1982)
Rat, Sprague-Dawley (SD), male and female | Oral gavage | 9 mg/kg and 17.5 mg/kg K_2_Cr_2_O_7_, 7 d | ↓ free radical scavenging capacity (benzoic acid hydroxylation method); ↓ GSH | Dose-dependent decreases | Zhong et al. (2017c)
Rat, Wistar, female | Oral drinking water | 5 and 20 mg/L K_2_Cr_2_O_7_, 15 d | Null results CYP2E1 activity; ↓ GSH (at both doses) | | Ma et al. (2015)
Rat, Sprague-Dawley, male | i.p. | 2.5, 5.0, 7.5, and 10 mg/kg-d K_2_Cr_2_O_7_, 5 d | ↑ ROS, MDA; ↑ SOD, CAT activity | Results dose dependent | Patlolla et al. (2009b)
Mouse, ddY, male | i.p. | 20 mg/kg K_2_Cr_2_O_7_, single dose, reports at 24 and 48 hr | ↑ lipid peroxidation (TBARS) | | Susa et al. (1989)
Rat, Sprague-Dawley, male | i.p. | 10–40 mg/kg Na_2_Cr_2_O_7_, single dose | ↑ GSH 20 mg/kg | | Standeven and Wetterhahn (1991b)
Mouse, Swiss albino, male | i.p. | 1 mg/kg CrO_3_, single dose, reports at 5–8 wk | ↑ SOD, peroxidase, CAT, lipid peroxidation, ascorbic acid content in liver tissue | Mice from live animal supply farm, “around” 48 mice range from 15 to 25 g body weight. Increases were not time dependent | Acharya et al. (2004a)
Rat, Wistar, male | i.p. | 20 mg/kg body weight of K_2_Cr_2_O_7_, single dose; 3-min, 3-hr, 24-hr time course | ↑ SOD at 24 h Null for changes in CAT, lipid peroxidation (TBARS), CYP450 | | Tagliari et al. (2004b)
Rat, Wistar, male | i.p. | 20 mg/kg K_2_Cr_2_O_7_, single IP dose, 24 h | ↑ lipid peroxidation, GSH level and GPx-1 activity; no change in GR activity; ↓ TrxR-1 activity | | Kotyzova et al. (2015)
Mouse, BALB/c | i.p. | 0 or 400 μmol K_2_Cr_2_O_7_ (20.8 mg Cr(VI)/kg), single dose | In liver:; ↑ lipid peroxidation (p < 0.05); ↑ heme oxygenase (p < 0.001); ↓ GSH-peroxidase activity (p < 0.1); slight but nonsignificant reduction in GSH levels | Significantly decreased %PCEs (PCE/NCE ratio = 0.64 ± 0.14) (p < 0.01); Also ↑ micronucleus frequency in bone marrow cells (p < 0.001) | Wroñska-Nofer et al. (1999)
HepG2 cells (human hepatocytes) | In vitro | 5, 10, 20, 40 μM K_2_Cr_2_O_7_ | ↑ SOD, Nrf2, Keap1 mRNA at 10 μM; ↑ SOD, Nrf2, Keap1 mRNA over 10 μM | In a separate study X. Zhong shows SOD activity decrease starting at 1 μM but in L-02 (human fetal) cells | Zhong et al. (2017a)
HepG2 cells (human hepatocytes) | In vitro | 3–25 μM K_2_Cr_2_O_7_ | ↑ ROS production and MDA ≥ 12.5 μM | | Patlolla et al. (2009a)
Hep3B cells (human hepatocytes) | In vitro | 20 μM K_2_Cr_2_O_7_ | ↑ levels of SOD, GR, NO, CAT, MDA | | Zeng et al. (2013)
L-02, human fetal hepatocytes | In vitro | | ↑ Endoplasmic reticulum stress and mitochondrial damage, and apoptosis; effects reversed by antioxidant treatment | | Liang et al. (2019)
L-02 cells (human fetal liver) | In vitro | Various (Yuan 1–32 μM; Xiao 2012 4–32 μM Xei 4 μM for caspase 3/beclin, Ca+2 and ROS; Xiao 2014 25 μM typically used for experiments (65%–75% survival rate); Zhang 2016 10 nM for ROS, MRCC, p53); all units in Cr(VI) (parent compound was K_2_Cr_2_O_7_) | ↑ ROS production (Zhang 2016; Yuan 2012; Xiao 2012); ↑ CHOP, PERK, IRE1 mRNA and protein (ER stress 6–10 μM, Zhang 2017); ↓ SOD, TRx, and GHS (Zhong 2017a, 8 and 16 μM dose dependent) | Doses not overtly cytotoxic, could be some decline in viability. Zhang 2016, Xiao 2012, Yi 2016, Zhong 2017a and Yuan 2015 measured ROS with DCF | Zhong et al. (2017c); Zhang et al. (2016); Zhang et al. (2017); Yuan et al. (2012); Yi et al. (2016); Xiao et al. (2012a); Xiao et al. (2012b)
Mitochondrial dysfunction
Rat, Sprague-Dawley, female | Drinking water | 10 mg/kg-d and 2.5 mg/kg-d Na_2_Cr_2_O_7_, respectively; 90 d and 120 d | ↑ hepatic mitochondrial and microsome peroxidation with concurrent excretion of lipid metabolites | This is the same study/effect listed above under oxidative stress | (Bagchi et al., 1995a; Bagchi et al., 1997b)
Mouse, female C57BL/6NTac N12 p53-deficient C57BL/6TSG-p53 | Assume by gavage | 2000 and 2002: 0.50 LD_50_, 0.10 LD_50_, 0.01 LD_50_.; 2001: 0.50 LD_50_ reported as 95 mg/kg; Na_2_Cr_2_O_7_ after 24 hr. 24 hr, 24 hr, and time course up to 96 hr respectively | ↑ hepatic cytochrome C (reported as SOA production); ↑ hepatic lipid peroxidation | Dosing and (n) not given (2000 and 2002). LD_50_ (2001) not consistent with LD_50_ reported in 1995b. | (Bagchi et al., 2000a; Bagchi et al., 2001); Bagchi et al. (2002a)
Mouse, ICR, male | Feed | 1 and 4 mg/kg/K_2_Cr_2_O_7_-d, 36 d repeat dose | ↑ cytochrome C | | Jin et al. (2014)
Mouse, Swiss albino, male | Gavage | 0, 25, 50, and 100 mg/kg; K_2_Cr_2_O_7_ single dose, 24 hr | ↑ cytochrome C (50&100 mg/kg) | | Wang et al. (2010b)
L-02 human fetal hepatocytes | In vitro | Various (Yuan 1–32 μM; Xiao 2012 4–32 μM Cr(VI); Xei 4 μM for caspase 3/beclin, Ca+2 and ROS; Xiao 2014 25 μM typically used for experiments (65–75% survival rate); Yi 2015 2–16 μM Cr(VI) for mitochondrial effects; Zhang 2016 10 nM 24 hr 2× for 4 wk – ROS, MRCC, p53), Zhong 2017a 8&16 μM; all units in Cr(VI) (parent compound was K_2_Cr_2_O_7_) | ↓ ATP production (Yuan 2012, Xie 2014; Xiao 2014);; ↓ mitochondrial respiratory chain complex (MRCC) I and II activity (25 μM Xiao 2014/ Zhang 2015, Zhong 2017a); ↓ MMP, ATP dose dependent (1–4 μM, Xie 2014); ↑ VDAC expression (protein&mRNA, accelerates movement of Ca^2+^ from ER to IMM; Yuan 2012, Yi 2017), Ca2+ effects | Xiao 2014 strong CC between mito ETC dysfunction and apoptosis | Zhong et al. (2017c); Zhang et al. (2016); Yuan et al. (2012); Yi et al. (2017); Xie et al. (2014); Xiao et al. (2012a); Xiao et al. (2012b); Xiao et al. (2014)
HepG2 human hepatocytes | In vitro | 5, 10, 20, 40 μM; K_2_Cr_2_O_7_ | ↑ mtDNA copy number, mt mass, NDUFA1, Foxo1, Sirt1, Akt1, Creb1, ATP50 and ATP3J gene expression at 10 μM; ↓ mtDNA copy number, mt mass, NDUFA1, Foxo1, AKT1, Creb1, MAPK2, Pten, ATP50 and ATP3J gene expression over 10 μM | | Zhong et al. (2017a)
L-02 human fetal hepatocytes | In vitro | 1–4 μM K_2_Cr_2_O_7_, 24 h | ↓ ETFDH, CoQ10, ATP production, SOD, Bcl-2; ↑ ROS, caspase-3, caspase-9, MDA (lipid peroxidation), mitochondrial membrane depolarization and permeability transition pore (MPTP) opening, Ca2+, Cyt c release, Bax | Cr(VI) induces CoQ10 deficiency (essential for cellular respiration and metabolism); effects reversed by pretreatment with CoQ10 | Zhong et al. (2017b)
Inflammation
Mouse, ICR, male | Feed | 1 and 4 mg/kg/K_2_Cr_2_O_7_-d, 36 d repeat dose | ↑ Ho-1 | | Jin et al. (2014)
Rat, Wistar, male | Gavage | 30mg/kg/K_2_Cr_2_O_7_-d, 28 d repeat dose | ↑ serum levels of ALT, AST, and ALP; ↑ TNFα, MAPK gene expression | | Navya et al. (2017)
Rat, Sprague-Dawley (SD), male and female | Gavage | 9 mg/kg and 17.5 mg/kg K_2_Cr_2_O_7_, 7 d | ↑ serum levels of ALT, AST (17.5 mg/kg) | | Zhong et al. (2017c)
L-02, human fetal hepatocytes | In vitro | 4 and 8 uM K_2_Cr_2_O_7_ (85%–80% viability Yi 2017); 2–32uM Yi 2016; Zhong 2017a 8–15 μM | ↑ ALT, AST leakage; ↑ TNFα, IL-1β, LBT4; ↑ Nf-kB p65 (Yi 2016, 16 μM) | All dose dependent | Zhong et al. (2017c); Yi et al. (2016); Yi et al. (2017)
Apoptosis
Mouse, ICR, male | Feed | 1 and 4 mg/kg/K_2_Cr_2_O_7_-d, 36 d repeat dose | ↑ Caspase 3, 7, 9; ↑ cytochrome C | ER stress response | Jin et al. (2014)
Rat, Wistar, male | Gavage | 30mg/kg/K_2_Cr_2_O_7_-d, 28-d repeat dose | ↓ Bcl-2 | | Navya et al. (2017)
Mouse, Swiss albino, male | Gavage | 0, 25, 50, and 100 mg/kg; K_2_Cr_2_O_7_ single dose, 24 hr | ↑ cytochrome C, p53, Casp 3; ↓ Bcl-2 (100 mg/kg) | | Wang et al. (2010b)
HepG2 cells (human hepatocytes) | In vitro | 5, 10, 20, 40 μM K_2_Cr_2_O_7_ | No significant change in cell viability at 10 μM; ↑ Significant (20%) decline in cell viability at 40 μM | | Zhong et al. (2017a)
HepG2 cells (human hepatocytes) | In vitro | 3–25 μM K_2_Cr_2_O_7_ | ↓ Significant (20%) decline in cell viability at 25 μM | | Patlolla et al. (2009a)
Hep3B cells (human hepatocytes) | In vitro | 2.5–100 μM K_2_Cr_2_O_7_ | ↓ cell viability at 10 μM (10%), 20 μM (20%); ↑ caspase activity 20 μM | | Zeng et al. (2013)
L-02 human fetal hepatocytes | In vitro | | ↑ autophagosomes, LC3-II, and protein degradation;; ↓ p62/SQSTM1 | Autophagy associated with ROS-AKT-mTOR pathway; Autophagy blocked by antioxidants; Inhibition of autophagy induced apoptosis | Liang et al. (2018)
L-02 human fetal hepatocytes | In vitro | Various (Yuan 1–32 μM; Xiao 2012 4–32 μM; Xei 4 μM for caspase 3/beclin, Ca+2 and ROS; Xiao 2014 25 μM typically used for experiments (65%–75% survival rate 12 hr); Yi 2015 2–16 μM for mitochondrial effects; Zhang 2016 10 nM 24 hr 2× wk for 4 wk); all units in Cr(VI) (parent compound was K_2_Cr_2_O_7_) | ↑ p53 (Zhang 2016); ↑ Caspase 3 (25 μM Xiao 2014, Xie 2014 activity 1–4 μM 24 hr; Xiao 2012 dose dependent); ↑ apoptosis (25 μM, Xiao 2014; sig at 8 μM in Yuan 2012); ↑ Beclin-1 mRNA (1–4 μM, Xie 2014); ↓ Bcl-2, ↑ Bax&cyto C (Zhang 2017 dose dependent 6–10 μM) | | Yuan et al. (2012); Xiao et al. (2012a); Xiao et al. (2012b); Xie et al. (2014); Xiao et al. (2014); Zhang et al. (2016); Zhong et al. (2017c), Zhang et al. (2017)
L-02 human fetal hepatocytes | In vitro | 0, 5, 10, 15 μM Cr(VI) | ↑ Clusterin (CLU), dose dependent | Overexpression of CLU can counteract Cr(VI)-induced MRCC I inhibition, preventing apoptosis | Xiao et al. (2019)
DNA damage
Rat, Wistar, male | Gavage | 30 mg/kg/K_2_Cr_2_O_7_-d, 28 d repeat dose | ↓ OGG-1; ↑ GADD45 | | Navya et al. (2017)
Mouse, C57BL/J5 | Drinking water | Na_2_Cr_2_O_7_; dose range 55–5,500 μg/L, 5 mo, repeat dose; 2 animals per dose group | ↑ p73; ↑ P-γH2AX positive (no dose dependence) | For this study n = 2 males and 2 females | Sánchez-Martín et al. (2015)
Rat, Sprague-Dawley, female | Gavage | 25mg/kg Na_2_Cr_2_O_7_ (reported as 0.5 LD_50_), single dose | ↑ DNA SSBs in hepatic tissue | (n) not given | Bagchi et al. (1995b), Stohs et al. (2001)
Mouse, female C57BL/6NTac N12 p53-deficient C57BL/6TSG-p53 | Assume by gavage | 2000&2002: 0.50 LD_50_, 0.10 LD_50_, 0.01 LD_50_.; 2001: 0.50 LD_50_ = 95 mg/kg Na_2_Cr_2_O_7_, single dose (?), 48 hr, 24 hr, up to 96 hr time course, respectively | ↑ DNA fragmentation in hepatic tissue | Dosing and (n) not given (2000 and 2002), DNA fragmentation measured by % 600-nm absorbance in supernatant (2000). DNA fragmentation by electrophoresis (2001) | (Bagchi et al., 2000a; 2001); Bagchi et al. (2002a)
Rat, Fischer 344, male | Drinking water | 100 and 200 mg/L K_2_Cr_2_O_7_, 3 wk | ↑ hepatic DPCs | Quantitative analysis performed but not presented, results not visually convincing | Coogan et al. (1991a)
Rat, Wistar, female | Drinking water | 5 and 20 mg/L K_2_Cr_2_O_7_, 15 d | Null results for O6-MeG adducts | | Ma et al. (2015)
Mouse, Swiss albino, female | Drinking water | 1.7 and 3.5 mg/L Na_2_Cr_2_O_7_ and 3.5 mg/L K_2_Cr_2_O_7_, 18 d (duration of pregnancy) | Null results for hepatic MN in fetuses | | De Flora et al. (2006)
Mouse, C56BL/6 Big Blue, female | Intra-tracheal instillation | 6.75 mg/kg K_2_Cr_2_O_7_, 28 d, single dose | ↑ mutation frequency in liver, but only compared with pooled controls (p = 0.043; not statistically significant compared with concurrent liver controls (p = 0.085) | MF higher in lung than in liver or kidney | Cheng et al. (2000)
Rat, Sprague-Dawley, male | Intra-tracheal instillation | 0.25 mg/kg Na_2_Cr_2_O_7_, 3 d | No effect on DNA-protein crosslinks, DNA fragmentation, 8-OHdG levels, or gene expression, including those associated with apoptosis, or various forms of DNA alterations in liver tissue | | D’Agostini et al. (2002); Izzotti et al. (1998); Izzotti et al. (2002)
Mouse, BDF1, female | i.p. | 25 mg/kg Na_2_Cr_2_O_7_ – acute; 12.5 mg/kg – subchronic, single injection for acute (1–14 d) or every 4 wk for 128 d | ↑ changes in ploidy in acute group | N ranged from 3 to 5 per group. All regions of liver | Garrison et al. (1990)
Rat, Sprague-Dawley, male | i.p. | 20 or 50 mg/kg-d Na_2_Cr_2_O_7_ | 1 h: DNA-DNA and DNA-protein crosslinks in liver, lung and kidney; ↑ DNA strand breaks in liver; 36–40 h: DNA-protein crosslinks in lung and kidney | | Tsapakos et al. (1981), Tsapakos et al. (1983)
Mouse, albino male | i.p. | 0 or 20 mg Cr(VI)/kg, single dose | DNA damage (comet assay), 15 min postinjection (all back to control levels at 3 h):; ↑ liver, kidney; No increases in spleen, lung, brain | Same pattern as Cr(V) complexes; Cytotoxicity not reported; DNA damage reduced with deferoxamine | Ueno et al. (2001)
Mouse | i.p. | 80 mg/kg K_2_Cr_2_O_4_ | DNA damage (comet assay) in liver, lung, kidney, spleen, and bone marrow | | Sasaki et al. (1997)
Hep3B cells (human hepatocytes) | In vitro | 20 μM K_2_Cr_2_O_7_ | ↑ DNA damage (30% comet cells) in p53-deficient Hep3B cells when caspase-3 was blocked | | Zeng et al. (2013)
HepG2 cells (human hepatocytes) | In vitro | 3–25 μM K_2_Cr_2_O_7_ | ↑ DNA damage (comet assay), dose-dependent | | Patlolla et al. (2009a)
Cell proliferation
Mouse, C57BL/J5 | Drinking water | Na_2_Cr_2_O_7_; dose range 55–5,500 μg/L, 5 mo, repeat dose; 2 animals per dose group | ↓ p16 and p19 | For this study n = 2 males and 2 females | Sánchez-Martín et al. (2015)
Mouse, C57BL/J5 | Drinking water (in vitro study) | 10 nM K_2_Cr_2_O_7_ for 24 hr 2× wk for 4 wk, 5 mo, repeat dose | ↑ senescence | Cr(VI) concentration was chosen according to the Cr(VI) values recorded in the blood circulation of exposed workers | Zhang et al. (2016)

i.p. = intraperitoneal injection.

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.2.4 Hematological Effects

#### C.2.4.1 Mechanistic studies relevant to hematological effects

Mechanistic evidence indicating the biological pathways involved in hematological toxicity following Cr(VI) exposure is summarized in Table C-35. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “hematology” if involving red blood cells (erythrocytes) or reporting other endpoints relevant to hematological toxicity (e.g., measures of hemoglobin levels). Studies were prioritized for consideration in the synthesis of mechanistic evidence for hematological effects if they were conducted in mammalian species:

- Studies in humans with quantified oral or inhalation exposure to Cr(VI)
- Studies in experimental animals with quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation exposure to Cr(VI)
- In vitro studies in human primary erythrocytes
- Mechanistic endpoints relevant to interpretations of hematological effects in humans

Twelve hematological studies were identified to include in the mechanistic syntheses, including four drinking water exposure studies in rats and mice, one i.p. injection study in mice, and seven investigations using human primary erythrocytes.

Table C-35 Mechanistic studies prioritized for informing potential Cr(VI)-induced hematological effects

System/route | Exposure^a^ | Results/comments | Reference
Rat, Wistar, male | 700 mg/L K_2_Cr_2_O_7_ (67 mg/kg) in drinking water, 14 d | In plasma: ↑ IL-1β, TNF-α, 8-iso-PGF(2a), and creatinine; In plasma and urine: ↑ 11-dehydro-TXB2; Markers indicating arachidonic acid peroxidation | Mitrov et al. (2014)
Rat, Wistar females, GD 9–21; Oral, drinking water | 0, 50, 100, 200, and 400 mg/L K_2_Cr_2_O_7_ | In pregnant rats:; ↓ RBC counts, hemoglobin, hematocrit, and MCV levels at 200 and 400 mg/L | Samuel et al. (2012)
F344 rats and B6C3F1 mice; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI), 90 d; 0, 0.015, 0.21, 2.9, 7.2, 20.5 mg/kg-d Cr(VI) (rats); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI) (mice) | Dose-dependent decreases in Fe levels in the duodenum, liver, serum, and bone marrow; Induction of divalent metal transporter 1 and transferrin receptor 1 in duodenum; ↑ Cr RBC:plasma ratios in rats ≥20.9 mg/L | Suh et al. (2014)
Rat, Sprague-Dawley; Oral, drinking water | 0, 30, 100, and 300 mg/L K_2_Cr_2_O_7_ (0, 10.6, 35.4, and 106.1 mg/L Cr(VI)); 0, 2.49, 7.57, 21.41 mg/kg-d Cr(VI); 4 wk | Mean body weight gain, mean water consumption, clinical chemistry determinations, and oxidative stress levels in plasma; Mild anemic effects and ↑ plasma malondialdehyde (MDA) levels correlated with ↓ global DNA methylation at 35.4 and 106.1 mg/L; ↓ plasma glutathione peroxidase (GSH-Px) activity (all exposed groups); No effect on p16 methylation or plasma 8-OHdG levels | Wang et al. (2015)
Mouse, Swiss; Intraperitoneal injection | 4 mg/kg-d K_2_Cr_2_O_7_, 5 d/wk, 2 wk | ↓ Hemoglobin, hematocrit, and RBC counts; Echinocytic transformation; Leucopenia after 2 wk | Ray and Sarkar (2012)
Human, primary erythrocytes | 0, 0.1, 0.5, 1.0, 2.5, and 5 mM K_2_Cr_2_O_7_, 1 hr | ↑ erythrocyte hemolysis and protein carbonyl content, dose-dependent; ↑ lipid peroxidation (MDA levels); ↓ total SH content, NO levels; ↑ SOD and glutathione S-transferase; ↓ catalase, G6PD, glutathione peroxidase, glutathione reductase, and thioredoxin reductase | Ahmad et al. (2011)
Human, primary erythrocytes | 0 or 8 mM Na_2_Cr_2_O_7_, 0, 2, and 4 hr | ↑ lipid peroxidation (TBARS) ≥2 h; No hemolysis, but observed echinocytic transformation of RBCs; ↓ GSH levels and GSSG-R activity; No effect on catalase, GSH-Px, or SOD activities; ↑ methemoglobin (hemoglobin oxidation) and ↓ NADH-methemoglobin reductase activity in RBCs | Fernandes et al. (1999)
Human, primary erythrocytes | 5–25 μg Cr(VI)/L blood | ↓ glutathione reductase; No effect on other erythrocyte enzymes | Koutras et al. (1964)
Human, primary erythrocytes | 0, 1, 10, or 20 μM Cr(VI), 48 hr | Evidence of eryptosis (apoptotic-like death of erythrocytes): ↑ intracellular Ca^2+^, ↓ ATP, ↓ cell volume, ↑ annexin-V (phosphatidylserine) binding; ↑ hemolysis; No effect on ceramide formation (inconsistent with eryptosis) | Lupescu et al. (2012)
Human, primary erythrocytes and mitochondria from placenta tissue | 0.05, 0.5, 1, 5 μg/mL K_2_Cr_2_O_7_ | ↑ lipid peroxidation level (TBARS) (decreased with coadministration of estrogen metabolite 4-OHE2); ↓ SOD and GST activity; ↓ nitric oxide levels in blood | (2017); Sawicka and Długosz (2017)
Human, primary erythrocytes | 0, 1.25, 2.5, 5, 10, 20, 40, 80, and 160 μM Cr(VI), 48 hr | ↑ hemolysis, dose dependent; Evidence of eryptosis: ↑ intracellular Ca^2+^, ↓ ATP, ↓ cell volume, ↑ annexin-V (phosphatidylserine) binding; Blocking Ca influx lessened cell volume reduction; ↑ ROS; incubation with NAC did lower ROS levels but did not affect annexin-V binding | Zhang et al. (2014)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; Sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.2.5 Immune Effects

#### C.2.5.1 Immune toxicity evidence tables

The immune evidence from experimental animals synthesized in Section 3.2.6 of the toxicological review is summarized in Table C-36. These studies were identified using the main PECO criteria in Appendix A and screened for outcomes that inform Cr(VI)-induced immune toxicity. The evidence is organized by the immune toxicity endpoints identified in the World Health Organization’s Guidance for Immunotoxicity Risk Assessment for Chemicals (Ipcs, 2012).

Table C-36 Data summary tables for immunological outcomes included in the immune effects animal evidence synthesis

Reference | Species (strain) | Exposure design | Dose^a^ | Exposure route | Endpoint | Results
Host resistance
Cohen et al. (2006) | Rats (male, F344) | Short-term (5 d) | 118.57 μg/m^3^ for 5 hr/d for 5 consecutive d | Inhalation | Pathogen clearance | Decreased 72 hr postinfection, but not 24 or 48 hr postinfection and only in the high-dose group. Effect observed in both soluble and insoluble forms of Cr(VI), but the effect was not correlated with chromium lung burden.
Cohen et al. (2010) | Rats (male, F344) | Short-term (5 d) | 118.57 μg/m^3^ for 5 hr/d for 5 consecutive d | Inhalation | Pathogen clearance | Decreased 72 hr postinfection, but not 24 or 48 hr postinfection and only in the high-dose group. Effect observed in both soluble and insoluble forms of Cr(VI), but the effect was not correlated with chromium lung burden.
Antibody responses
NTP (2005) | Mice (female, B6C3Fl) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | IgM AFC/10^6^ cells | Increased ~30% for 31.3 and 62.5 mg/L; Not reproducible in second assay.
NTP (2005) | Mice (female, B6C3Fl) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | IgM AFC/spleen | 34% incr. for 62.5 mg/L dose only.; Not reproducible in second assay.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | IgM AFC/10^6^ cells | No effect.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | IgM AFC/spleen | No effect.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | IgM AFC/10^6^ cells | 66% incr. at 57.3 mg/L dose only.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | IgM AFC/spleen | 62% incr. at 57.3 mg/L dose only.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Short-term (28 d) | 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | # spleen cells necessary for lysis of 50% hemolysis SRBCs | No effect.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Subchronic (90 d) | 0.025, 0.050, 0.10, 0.20 mg/m^3^ | Inhalation | # spleen cells necessary for lysis of 50% hemolysis SRBCs | Increased response for 0.050 mg/m^3^, 0.050 mg/m^3^ + 2-mo recovery and 0.20 mg/m^3^ groups.
Ex vivo WBC function
NTP (2005) | Mice (female, BC3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | MLR | No effect.
NTP (2005) | Mice (female, BC3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | NK cell activity | No effect.
NTP (2005) | Mice (female, BC3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Spleen cell proliferation | No effect on anti-CD3 spleen cell proliferation.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | NK cell activity | No effect.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Spleen cell proliferation | No effect on anti-CD3 spleen cell proliferation.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | NK cell activity | No effect.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Spleen cell proliferation | No effect on anti-CD3 spleen cell proliferation.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Short-term (28 d) and subchronic (90 d) | Short-term (0.050 mg/m^3^), subchronic (0.025, 0.050, 0.20 mg/m^3^) | Inhalation | Phagocytosis | For both exposure regimens, phagocytosis significantly increased at lower Cr(VI) levels (up to 0.050 mg/m^3^). Following subchronic exposure to 0.20 mg/m^3^, phagocytosis decreased significantly. In both instances, the investigators verified cellular viability prior to initiating the assay.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Subchronic (90 d) | 0.20 mg/m^3^ | Inhalation | Spleen cell proliferation | Compared with control, ConA stimulated T cell proliferative response (30 μg/mL, not 15 μg/mL ConA) was elevated in rats exposed to Cr(VI).
Shrivastava et al. (2005b) | Mice (Swiss) | Short-term and subchronic (3, 6, 9 wk) | 14.8 mg/kg | Drinking water | Phagocytosis | Compared with wk 0, phagocytosis of spleen macrophages was significantly reduced to 36% ± 7% at the 9-wk timepoint.
Shrivastava et al. (2005b) | Mice (Swiss) | Short-term and subchronic (3, 6, 9 wk) | 14.8 mg/kg | Drinking water | Spleen cell proliferation | Compared with wk 0, ConA stimulated T cell proliferative response was increased two-fold in mice exposed to Cr(VI), but the investigators did not analyze the findings statistically.
Snyder and Valle (1991) | Rat (F344) | Short-term (3 or 10 wk) | 100, 200 m/L | Drinking water | Spleen cell proliferation | Compared with control, proliferative response to ConA was elevated at 100 mg/L and decreased at 200 mg/L in splenocytes isolated from rats exposed to chromium in drinking water.; Response to LPS was increased at 100 mg/L and similar to control at 200 mg/L (3-wk exposure) in splenocytes isolated from rats exposed to chromium in drinking water. No dose-related pattern apparent.
Snyder and Valle (1991) | Rat (F344) | Short-term (3 or 10 wk) | 100, 200 m/L | Drinking water | MLR | Chromium (100 mg/L) had no effect on thymidine uptake from rats exposed for 10 wk unless splenocytes were cultured in the presence of 0.1 mg/L chromate; investigators did not analyze findings statistically.
Cohen et al. (1998) | Rat (F344) | Short-term (28 d) | 360 μg/m^3^ | Inhalation | Reactive oxygen species; Nitric oxide | Potassium chromate had no effect on O_2_– or H_2_O_2_ production in the presence or absence of IFN-γ at 4 wk, but increased opsonized zymosan-stimulated O_2_– and decreased H_2_O_2_ production in the presence IFN-γ.; Chromium had no effect on LPS-stimulated nitric oxide production at 4 wk, but reduced IFN-g-stimulated production at 4 wk.
Cohen et al. (1998) | Rat (F344) | Short-term (28 d) | 360 μg/m^3^ | Inhalation | Mitogen-stimulated cytokine production (LPS) by pulmonary alveolar macrophages exposed in vivo for 4 wk. | Decreased IL-1, TNFα; Nonstatistically significant increase in IL-6.
Johansson et al. (1986) | Rabbit (strain not specified) | Chronic | 0.9 ± 0.4 mg/m^3^ | Inhalation | Phagocytosis | No effect.; Note: Study outcome could have been affected by the 3 d gap between exposure to chromium and evaluation of effects on phagocytosis.
Karaulov et al. (2019) | Rat (Wistar) | Chronic | 20 mg/kg-d | Drinking water | Mitogen-stimulated cytokine production (ConA) by splenocytes exposed in vivo for 45, 90, or 135 d | Increased IL-4 (d 45, 90, and 135) and decreased IL-6 (d 135).; No effect on IL-10 and IFNγ.
Immune organ pathology
NTP (2005) | Mice (female, B6C3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Gross spleen and thymus lesions | No effect.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Gross spleen and thymus lesions | No effect.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Gross spleen and thymus lesions | No effect.
NTP (2007f) | Rats (male and female, F344) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular, mesenteric, and pancreatic) | No effect.; Note: Although the effect is unlikely to be due to immunotoxicity, histiocytic cellular infiltration of pancreatic lymph nodes was reported in male (≥125 mg/L) and female (l,000 mg/L) rats.
NTP (2007f) | Mice (male and female, B6C3F1) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular, mesenteric, and pancreatic) | No effect.; Note: Although the effect is unlikely to be due to immunotoxicity, histiocytic cellular infiltration of mesenteric lymph nodes was reported in male and female mice exposed to 125 mg/L or more.
NTP (2007f) | Mice (male, BALB/c) | Subchronic (3 mo) | 62.5, 125 and 250 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular, mesenteric, and pancreatic) | No effect.
NTP (2007f) | Mice (male, am3-C57BL/6) | Subchronic (3 mo) | 62.5, 125 and 250 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular, mesenteric, and pancreatic) | No effect.; Note: Although the effect is unlikely to be due to immunotoxicity, histiocytic cellular infiltration of mesenteric lymph nodes was reported in male mice exposed to 250 mg/L.
NTP (2008) | Rat (male and female, F344/N) | 2 yr (d 22, 6 and 12 mo) | 14.3, 57.3, 172, or 516 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular and mesenteric) | No effect.; Note: Although the effect is unlikely to be due to immunotoxicity, histiocytic cellular infiltration of mesenteric and pancreatic lymph nodes was reported in male and female rats exposed to 57.3 mg/L or greater.
NTP (2008) | Mice (male and female, B6C3F1) | 2 yr (d 22, 6 and 12 mo) | Male and female rats – 14.3, 57.3, 172, 516; Male mice – 14.3, 28.6, 85.7, or 257.4 mg/L SDD; Female mice – 14.3, 57.3, 172, or 516 mg/L SDD | Drinking water | Gross spleen and thymus lesions; Histopathology on spleen, thymus, lymph nodes (mandibular and mesenteric) | No effect.; Note: Although the effect is unlikely to be due to immunotoxicity, histiocytic cellular infiltration of the mesenteric lymph nodes of all exposed groups of males and females and of the pancreatic lymph nodes of 85.7 and 257.4 mg/L males and 172 and 516 mg/L females.
Karaulov et al. (2019) | Rats (male, Wistar) | Chronic (135 d) | 20 mg/kg-d | Drinking water | Histopathology of spleen, thymus, lymph nodes | Compared with control, structural changes including decreased reticular epitheliocytes and associations with T cells that could lead to functional impairment of the central immune system, data not reported for other timepoints.
Karaulov et al. (2019) | Rats (male, Wistar) | Chronic (135 d) | 20 mg/kg-d | Drinking water | Histopathology of spleen, thymus, lymph nodes | Compared with control, structural changes structural effects including increased B-zone and a decrease in the T-zone were observed in spleens across all timepoints.
Karaulov et al. (2019) | Rats (male, Wistar) | Chronic (135 d) | 20 mg/kg-d | Drinking water | Histopathology of spleen, thymus, lymph nodes | Lymph node size was increased and was attributed to changes in cellular elements.
NTP (1996) | Mice (female, BALBC) | Subchronic (90 d) | 15, 50, 100, 400 mg/L PDC | Oral diet | Gross spleen and thymus lesions | No effect.
Glaser et al. (1986) | Rats (male, Wistar TNO-W 74) | Chronic (18 mo exposure + 12 mo recovery) | 0.025, 0.050, 0.010 mg/m^3^ Cr(VI) | Inhalation | Histopathology of spleen | No effect.; Note: Animals were evaluated only after the full 30-mo study duration (i.e., including the 12-mo recovery period).
Immunoglobulin levels
NTP (2005) | Mice (female, B6C3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Antigen-specific IgM | No effect on serum titers of antigen-specific IgM (SRBC).
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Antigen-specific IgM | No effect on serum titers of antigen-specific IgM (KLH).
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Antigen-specific IgM | No effect on serum titers of antigen-specific IgM (SRBC).
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Short-term (28 d) | 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | Total serum Ig | Total serum Ig data not shown or mentioned in the results.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Subchronic (90 d) | 0.025, 0.050, 0.10, 0.20 mg/m^3^ | Inhalation | Total serum Ig | Dose-responsive increase in total serum Ig, significant at concentrations ≥0.025 mg/m^3^, peaked at 0.10 mg/m^3^, and declined to control levels at 0.20 mg/m^3^.
Glaser et al. (1986) | Rats (male, Wistar TNO-W 74) | Chronic (18 mo exposure + 12 mo recovery) | Sodium dichromate – 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | Total serum Ig | According to the investigators, total serum Ig levels decreased in all sodium dichromate exposure groups and for all timepoints (monthly for first 6 mo, every 3 mo thereafter), but observed effects were not significant; data not shown.
Glaser et al. (1990) | Rats (male, albino Wistar) | Short-term (30 d) | 0.050, 0.10, 0.20, 0.40 mg/m^3^ | Inhalation | Total serum Ig | No effect on total serum Ig levels; data not shown.
Glaser et al. (1990) | Rats (male, albino Wistar) | Subchronic (90 d) | 0.050, 0.10, 0.20, 0.40 mg/m^3^ | Inhalation | Total serum Ig | No effect on total serum Ig levels; data not shown.
Glaser et al. (1990) | Rats (male, albino Wistar) | Subchronic + recovery (90 d + 30 d recovery) | 0.050, 0.10, 0.20, 0.40 mg/m^3^ | Inhalation | Total serum Ig | No effect on total serum Ig levels; data not shown.
Immune organ weight
NTP (2005) | Mice (female, B6C3Fl) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | Nonreplicated decrease in relative spleen weight (31.3 mg/L).; No effect on relative thymus weight.; Note: Since significant changes in body weight were reported, absolute weights are not reliable.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Absolute spleen, thymus, and lymph node weight | No effect (spleen, thymus).; Protocol indicates lymph node weight was collected, but data were not reported.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Absolute spleen, thymus, and lymph node weight | No effect (spleen, thymus).; Protocol indicates lymph node weight was collected, but data were not reported.
NTP (2007f) | Rats (male and female, F344/N) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | Males – Relative spleen weights of 250 and 500 mg/L significantly less than control. Thymus weight unaffected.; Females – Relative spleen weights of 500 and 1,000 mg/L significantly less than control. Thymus weight unaffected.
NTP (2007f) | Mice (male and female, B6C3F1) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | Males – No effect on absolute spleen or thymus weight. Increased relative spleen and thymus weight (500 mg/L and 1,000 mg/L).; Females – No effect on spleen weight. Absolute thymus weight increased for single dose group. Relative thymus weight increased for 125, 250, 500, and 1,000 mg/L dose groups.; NOTE: Effects on organ weight were attributed to reduced body weights of the mice.
NTP (2007f) | Mice (male, B6C3F1) | Subchronic (3 mo) | 62.5, 125, and 250 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | Absolute thymus weight decreased (250 mg/L), considered treatment related.; Spleen weight unaffected.
NTP (2007f) | Mice (male, BALB/c) | Subchronic (3 mo) | 62.5, 125, and 250 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | No effect on spleen or thymus weight.
NTP (2007f) | Mice (male, am3-C57BL/6) | Subchronic (3 mo) | 62.5, 125, and 250 mg/L SDD | Drinking water | Absolute and relative spleen and thymus weight | Significant decrease in absolute thymus weight and relative spleen weights (250 mg/L); NOTE: Effects on organ weight were attributed to reduced body weights of the mice.
Karaulov et al. (2019) | Rats (male, Wistar) | Chronic (135 d) | 20 mg/kg-d | Drinking water | Absolute spleen and thymus weight | Absolute spleen and thymus weight decreased in rats exposed to chromium in drinking water for up to 135 d.
Shrivastava et al. (2005b) | Mice (male, Swiss) | Short-term and subchronic (3, 6, 9 wk) | 14.8 mg/kg | Drinking water | Relative spleen weight | Compared with wk 0, relative spleen weight decreased gradually and achieved statistical significance at the 9-wk timepoint.
Jin et al. (2016) | Mouse (male, ICR) | Short-term | 50 mg/L for 7 d or 200 mg/L for 21 d | Drinking water | Relative spleen weight | Compared with control, relative spleen weight was significantly increased following exposure to 50 mg/L potassium dichromate on d 7.; Compared with control, relative spleen weight was increased following exposure to 50 mg/L potassium dichromate for 21 d, but the effect was not significant.
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Short-term (28 d) | 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | Relative spleen weight | Compared with control, relative spleen weight increased for concentrations (≥0.050 mg/m^3^).
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Subchronic (90 d) | 0.025, 0.050, 0.10, 0.20 mg/m^3^ | Inhalation | Relative spleen weight | Compared with control, relative spleen weight increased for concentrations (≥0.050 mg/m^3^).
Glaser et al. (1986) | Rats (male, Wistar TNO-W 74) | Chronic (18 mo exposure + 12 mo recovery) | Sodium dichromate – 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | Spleen weight | No effect on spleen weight (relative or absolute not specified).; Note: animals were evaluated only after the full 30-mo study duration (i.e., including the 12-mo recovery period).
Kim et al. (2004) | Rats (male, Sprague-Dawley) | Subchronic (13 wk) | 0.2, 0.5, 1.25 mg/m^3^ | Inhalation | Relative spleen weight | No effect on relative spleen weight.
WBC counts (spleen cells)
NTP (2005) | Mice (female, BC3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Total WBCs; Absolute and relative splenic phenotypic analysis | No effect on total WBC counts.; No effect on splenic absolute or relative levels; B cells (ig+), T cells (CD3+), T helper cells (CD4+/CD8), T cytotoxic cells (CD4−/CD8+), immature T cells (CD4+/CD8+), and monocytes (Mac-3+ cells).
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Total WBCs; Absolute and relative splenic phenotypic analysis | No effect on total WBC counts.; No effect on splenic absolute number of B cells (CD45+), T cells (CD5+), T helper cells (CD4+/CD5+), T cytotoxic cells (CD8+/CD5+), and NK cells (CD8+).; Percent macrophages increased in low and high dose Cr(VI) groups; no other subpopulations affected.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Total WBCs; Absolute and relative splenic phenotypic analysis | No effect on total WBC counts.; No effect on splenic absolute and relative numbers of B cells (CD45+), T cells (CD4+/CD5+), T helper cells (CD4+), and T cytotoxic cells (CD8+/CD5+).; Absolute number of macrophages (HIS36+) increased at low dose. Increased NK cells (~40% change, single dose level 172 mg/L) and macrophages (~35% change, single dose level 14.3 mg/L).
Karaulov et al. (2019) | Rats (male, Wistar) | Chronic (135 d) | 20 mg/kg-d | Drinking water | Total WBCs; Absolute and relative splenic phenotypic analysis | No effect on WBC counts after 90 d exposure.; Decreased absolute number splenic karyocytes and myeloid cells.; Timepoint-specific effects on absolute number splenic plasma cells.; Absolute number of CD3+ cells decreased on d 90 and 135.; Relative number of CD3+ cells unaffected.; Absolute number of CD4+ cells decreased on d 90 and 135.; Relative number of CD4+ cells decreased on d 45.; Absolute and relative number of CD8+ cells decreased on d 90.; Absolute number of thymocytes decreased, but a dose-response was not evident.; Increased absolute number bone marrow myeloid cells, lymphocytes, neutrophils, and karyocytes at the 135 d timepoint.
WBC (hematology)
NTP (2005) | Mice (female, B6C3F1) | Short-term (28 d) | 15.6, 31.3, 62.5, 125, 250 mg/L SDD | Drinking water | Hematology | No effect.
NTP (2006b) | Rats (female, Sprague-Dawley) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Hematology | No effect.
NTP (2006a) | Rats (female, F344) | Short-term (28 d) | 14.3, 57.3, 172, 516 mg/L SDD | Drinking water | Hematology | No effect.
NTP (2007f) | Mice (male and female, B6C3F1) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Hematology | No effect, either sex.
NTP (2007f) | Mice (male, BALB/c) | Subchronic (3 mo) | 62.5, 125 and 250 mg/L SDD | Drinking water | Hematology | No effect.
NTP (2007f) | Mice (male, am3-C57BL/6) | Subchronic (3 mo) | 62.5, 125 and 250 mg/L SDD | Drinking water | Hematology | No effect.
NTP (2007f) | Rats (male and female, F344/N) | Subchronic (3 mo) | 62.5, 125, 250, 500, and 1,000 mg/L SDD | Drinking water | Hematology | Elevated WBC and lymphocytes in males and females, primarily in high dose groups (500 and 1,000 mg/L).; Increased neutrophil and monocyte counts (at higher exposures in males and females) were reported to be an inflammatory response associated with lesions observed histopathologically (e.g., gastric lesions) and not believed to fully account for increased leukocyte numbers.
NTP (2008) | Rat (male and female F344/N) | 2 yr (d 22, 6 and 12 mo) | 14.3, 57.3, 172, or 516 mg/L SDD | Drinking water | Hematology | Increased WBC, neutrophils and eosinophils, sporadically with time and generally in higher dose groups.
NTP (2008) | Mice (male and female, B6C3F1) | 2 yr (d 22, 6 and 12 mo) | Male and female mice – 14.3, 57.3, 172, 516; Male mice – 14.3, 28.6, 85.7, or 257.4 mg/L SDD; Female mice – 14.3, 57.3, 172, or 516 mg/L SDD | Drinking water | Hematology | Increased WBC, monocytes, and basophils, but only on d 22 in the higher dose groups.; Neutrophils increased on d 22 in top two dose groups and at 12 mo for top dose group.; Lymphocytes increased for d 22 (14.3 mg/L–516 mg/L).
Shrivastava et al. (2005a) | Mice (Swiss) | Short-term and subchronic (3, 6, 9 wk) | 14.8 mg/kg | Drinking water | Hematology | WBC decreased significantly at the 3-wk timepoint. Compared with wk 0, the relative number of lymphocytes, granulocytes, and monocytes decreased significantly at all timepoints.
NTP (1996) | Mice (female, BALBC) | Subchronic (90 d) | 15, 50, 100, 400 mg/L PDC | Oral diet | Hematology | No effect.
Krim et al. (2013) | Rat (male, albino Wistar) | Short-term (30 d) | 15 mg/kg PDC | Oral gavage | Hematology | No effect.
Glaser et al. (1986) | Rats (male, Wistar TNO-W 74) | Chronic (18 mo exposure + 12 mo recovery) | Sodium dichromate – 0.025, 0.050, 0.10 mg/m^3^ | Inhalation | Hematology | No effect on total WBC counts observed in all sodium dichromate exposure groups and for all timepoints (monthly for first 6 mo, every 3 mo thereafter).
Glaser et al. (1985) | Rats (male, Wistar TNO-W 74) | Short-term (28 d) & subchronic (90 d) | Short-term (0.025, 0.050, 0.10 mg/m^3^) & Subchronic (0.025, 0.050, 0.10, 0.20 mg/m^3^ CrO_3_) | Inhalation | Hematology | No effect.
Glaser et al. (1990) | Rats (male, Wistar BOR:WISW) | Short-term (30 d) subchronic (90 d) | 0.050, 0.10, 0.20, 0.40 mg/m^3^ CrO_3_ | Inhalation | Hematology | Elevated blood WBCs (0.050–0.40 mg/m^3^) at 30 d and 90 d, effect lost after 30-d recovery period (following 90 d of exposure).
Kim et al. (2004) | Rats (male, Sprague-Dawley) | Subchronic (13 wk) | 0.2, 0.5, 1.25 mg/m^3^ | Inhalation | Hematology | No effect on total WBC counts.

SRBC = sheep red blood cell; KLH = keyhole limpet hemocyanin; MLR = mixed lymphocyte reaction; NK = natural killer; ConA = concanavalin A; LPS = liposaccharide.

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

#### C.2.5.2 Mechanistic studies relevant to immunotoxicity

Studies initially tagged as “mechanistic” in the preliminary title and abstract screening were further screened and tagged “immune” if they reported any immunotoxicological outcome. A large body of mechanistic information (329 studies) exists to inform the potential immunotoxicity of Cr(VI). Within this evidence base, studies were tagged with immune-related categories if they reported relevant outcomes: “chronic inflammation” (39 studies) or “immune suppression” (34 studies) if relevant to cancer (reviewed in Section 3.2.3 of the toxicological review) and “cytokines” if a study reported cytokine measures (28 studies). In addition, studies tagged as “dermal” in “potentially relevant supplemental material” were rescreened to identify allergic sensitization (68 studies) or immune stimulation (61 studies) outcomes that also appeared to involve nondermal exposures to Cr(VI).

Subsequent prioritization of the immune-relevant studies that are more informative for chronic human exposure was conducted to identify mammalian studies of the immune system that focused on exposure routes more relevant to humans (oral drinking water and inhalation) for durations ranging from short-term to chronic. In addition, supporting information in vitro studies in human and animal primary lymphocytes and cell lines provided insight into biological plausibility and human relevance of the observed mechanisms. These prioritization criteria are as follows:

- Studies in humans with quantified oral or inhalation exposure to Cr(VI)
- Studies in experimental animals with quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation exposure to Cr(VI)
- Ex vivo assays performed on immune-relevant cells exposed in vivo
- In vitro studies in primary or immortalized mammalian cells derived from immune organ or tissues
- Mechanistic endpoints relevant to interpretations of immune health effects in humans and animals

Fourteen studies were identified that primarily reported evidence of Cr(VI)-induced alterations in cell differentiation or activation, effector cell function, cell proliferation, and cell-cell communication; these studies are summarized in Table C-37. In addition, 21 studies reporting cytokine measures were prioritized; these studies are summarized in Table C-38.

Table C-37 Mechanistic studies prioritized for informing potential Cr(VI)-induced immune toxicity

System | Route | Exposure^a^ | Results | Comments | Reference
Effects on immune cell differentiation or activation
Human monocyte derived dendritic cells (MoDC) | Human monocyte derived dendritic cells (MoDC) | 25, 50, 75, 100 nM K_2_Cr_2_O_7_, 48 h | ↑ CD86 (dose dependence with significance at 100 nM); no change in CD83 | 100 nM K_2_Cr_2_O_7_ considered nontoxic dose when cells were 75% viable | Toebak et al. (2006)
Mouse splenocytes from male and female C57BL/6 | In vitro | 0, 2, 5 μM K_2_Cr_2_O_7_, 24 hr | ↓ activation of T cells stimulated with anti-CD3 and anti-CD28 (↓ CD69 at both doses and ↓ CD25 at 5 μM) | Significant ↓ CD4+ T cell viability at 5 μM, but not 2 μM | Dai et al. (2017b)
Effects on immune effector function of specific cell types
Mouse RAW264.7 macrophages | In vitro | 50 μg/mL welding fumes (250 μg/mL), 3 or 6 h | ↓ phagocytosis following exposure to Ni WF (50 μg/mL) at 3 and 6 hr timepoints, but not by other welding fumes | ↓ number live cells and percentage viable cells for all welding fumes (250 μg/mL) at 24 hr, but only Ni-Cu WF caused a reduction in live cells at 50 μg/mL; GMA-MS = Cr(VI) not detected; GMA-SS = 2,600 ± 120 μg/g Cr(VI); Ni-Cu WF = 422 ± 35 μg/g Cr(VI) | Badding et al. (2014))
Human primary lymphocytes | In vitro | K_2_Cr_2_O_7_, 7 d | ↓ IgG production at 0.1–10 μM w/80% reduction at 2 μM by lymphocytes stimulated with PWM | Effects correlated with Cr content in cells | Borella and Bargellini (1993)
Mouse (BALB/cABOM) primary peritoneal macrophages | In vitro | 0.313–40 μM, 18 hr (random migration) or 2.5 μM and 10 μM, 24 hr (phagocytosis) Na_2_CrO_4_ | No changes in random migration (chemokinesis) up to 2.5 μM, but ↓ random migration in concentrations at ≥5 μM for 18 hr in “stimulated” macrophages.; ↓ phagocytosis in resting macrophages at ≥2.5 μM, but not at lower concentrations | Viability not affected by 2.5 and 1.25 μM Cr(VI) during 28 d of exposure. 5 μM showed decreased viability after 48h. Chemokinesis studies carried out using stimulated macs, but stimuli not specified. | Christensen et al. (1992)
Mouse splenocytes from male and female C57BL/6 | In vitro | 0, 2, 5 μM K_2_Cr_2_O_7_, 24 hr | ↓ production cell surface expression of CD107a (indicates degranulation by CD8+ T cells) | Significant ↓ CD8+ T cell viability at 5 μM and 2 μM | Dai et al. (2017b)
Bovine alveolar macrophages | In vitro | 10–1000 μg/mL MMA-SS, MIG-SS, MMA-MS, MMA-CI, MIG-MS welding fumes, or K_2_CrO_4_, 18 hr | ↓ phagocytosis by 50% at 0.018 μg/mL K_2_CrO_4_; Welding fumes with higher Cr(VI) content decreased phagocytosis more potently than fumes containing less Cr(VI) | Inhibited phagocytosis at concentration ~10× less than the LC_50_ (i.e., 1.59 μg/mL) | Hooftman et al. (1988)
Human PMBCs from shoe, leather, and hide industry workers | Ex vivo/In vitro | PBMCs collected from exposed humans exposed Cr(VI) in vitro to 10^−5^ mg/L, 1 hr | ↑ percent phagocytosis, phagocytosis index and percent killing by PMNs collected from exposed workers and treated with Cr(VI) ex vivo | | Mignini et al. (2009)
Effects on immune cell proliferation
Human primary lymphocytes | In vitro | 0.1, 1, 10, 100 μM Cr(VI), 48 hr | ↓ anti-CD3 proliferation at all concentrations; ↓ anti-CD3/anti-CD28 proliferation at 10 and 100 μM | Cr(VI) test substance reported as CrO_3_ as source, given as ion concentration. Resting and CD3 activated lymphocytes showed decreased viability (to ~80%) at 1 μM, with drop after 10 μM. | Akbar et al. (2011)
Human primary lymphocytes | In vitro | K_2_Cr_2_O_7_, 4 d | ↑ proliferation by PHA-stimulated cells at 10^−8^–10^−6^ mol/L (4 d); ↓ proliferation by PHA-stimulated cells at 10^−6^–2.5 × 10^−6^ mol/L (4 d) | Biphasic pattern; effects correlated with Cr content in cells | Borella and Bargellini (1993)
Mouse splenocytes from male and female C57BL/6 | In vitro | 0, 2, 5 μM K_2_Cr_2_O_7_, 96 hf | ↓ proliferation by anti-CD3/anti-CD28 stimulated CD4+ T cells at 2 and 5 μM and CD8+ cells at 5 μM | Significant ↓ CD4+ T cell viability at 5 μM, but not 2 μM. | Dai et al. (2017b)
Rat splenocytes, Fischer 344 (splenocytes from Sprague-Dawley rats served as stimulator cells in the mixed lymphocyte cultures) | In vitro | LPS/ConA assay: 0.01–100 mg/mL K_2_CrO_4_, cells cultured “up to” 72 hr; Mixed lymphocyte response (MLR):; In vivo/ex vivo – 100 mg/L for 10 wk followed by 0.1 mg/L for 5 d of culture; In vitro – 0.1 mg/L K_2_CrO_4_, 5 d | ↓ mitogen stimulated proliferation by T lymphocyte (ConA) and B lymphocytes (LPS) cultures 0.1 mg/L and lower, no effect at higher doses; ↑ MLR in cells exposed in vivo and in vitro (no statistics); ↑ or no effect on MLR at 0.1 mg/L in vitro (statistics provided for only one of two experiments) | | Snyder and Valle (1991)
Cross-sectional study in Italy of 20 exposed and 24 unexposed workers | Ex vivo/In vitro | PBMCs collected from exposed workers treated with additional Cr(VI) ex vivo | No effect on ConA-stimulated proliferation in PBMCs collected from unexposed workers in the presence of Cr(VI) administered ex vivo; No effect on ConA-stimulated proliferation in PBMCs isolated from exposed workers and treated with Cr(VI) ex vivo; Nonsignificant biphasic response in Con-A stimulated proliferation in PBMCs collected from unexposed HLA-B8-DR3-negative subjects treated Cr(VI) ex vivo; No effect on Con-A stimulated proliferation in PBMCs collected from exposed HLA-B8-DR3-positive subjects treated Cr(VI) ex vivo; The effect of Cr(VI) exposure ex vivo on proliferation of lymphocytes collected from HLA-B8-DR3-negative and -positive subjects stimulated by ConA was investigated, but comparisons between exposed and unexposed subjects in the presence and absence of Cr(VI) were not reported.; ↓ ConA-stimulated proliferation in PBMCs collected from exposed HLA-B8-DR3-negative group treated with Cr(VI) in vitro in the absence of the monocytic/macrophage component.; The effect of Cr(VI) exposure ex vivo on proliferation of lymphocytes collected from HLA-B8-DR3-negative subjects stimulated by ConA in the absence of the monocytic/macrophagic component was investigated, but comparisons between exposed and unexposed subjects in the presence and absence of Cr(VI) were not reported. | | Mignini et al. (2004)
Cross-sectional study in Italy of 40 exposed tannery workers and 44 controls | Ex vivo/In vitro | Lymphocytes collected from exposed workers treated with additional Cr(VI) ex vivo | ↑ ConA- and PHA-stimulated proliferation in PBMCs collected from workers exposed to high concentration of Cr(VI) (Group B) ex vivo; No effect on LPS-stimulated proliferation in PBMCs collected from unexposed workers treated with low concentration of Cr(VI) ex vivo; ↑ ConA- and PHA-stimulated proliferation in PBMCs collected from unexposed workers treated with 10^−5 mg^/mL Cr(VI) in vitro; ↓ ConA- and PHA-stimulated proliferation in PBMCs collected from unexposed workers treated with 10^−2 mg^/mL Cr(VI) in vitro; ↑ LPS-stimulated proliferation in PBMCs collected from unexposed workers treated with 10^−2 mg^/mL or 10^−5 mg^/mL Cr(VI) in vitro; The effect of Cr(VI) exposure in vitro on proliferation of lymphocytes collected from exposed workers stimulated by ConA, PHA, and LPS was investigated, but comparisons between exposed and unexposed workers in the presence and absence of Cr(VI) were not reported. | | Mignini et al. (2009)
Effects on communication between immune cells
Human peripheral blood mononuclear cells from shoe, leather, and hide industry workers | Ex vivo/In vitro | PBMCs collected from exposed humans exposed to Cr(VI) in vitro to 10^−5^ mg/L, 1 h | No change in ICAM-1, VCAM, and ELAM-1E-selectin levels | | Mignini et al. (2009)
Human peripheral blood lymphocytes | In vitro | 588 μg/mL, 0.5 hr | No effect on E-rosetting | Data not shown | Bravo et al. (1990)
Cross-sectional study in China of 56 workers exposed to potassium dichromate and 50 unexposed individuals living 20 km from factory | In vivo | 14.4 ± 18.1 μg/m^3^ | C3 (g/L) – Exposed: 1.20 ± 0.24; Unexposed: 0.91 ± 0.13; C4 (g/L) – Exposed: 0.32 ± 0.07; Unexposed: 0.23 ± 0.05 | | Qian et al. (2013), low
Mouse splenic T cells | In vitro | 2 or 5 μM, 24 hr | Decreased anti-CD3/CD28-induced secretion of IL-2, IL-4, and IL-10 in splenocytes treated with 2 or 5 μM Cr(VI) | | Dai et al. (2017b)

See Table C-38 for effects on cytokine levels following Cr(VI) exposure.

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

Table C-38 Summary of cytokine levels measured following Cr(VI) exposure

Reference | Study design | Cytokines
Cytokines measured in blood, serum, and plasma
Kuo and Wu (2002) | Blood collected from Cr(VI)-exposed workers | ↑ IL-6 and IL-8; ↓ TNF-α (NS); No effect on IL-2, IL-4, IL-10, or IFN-γ
Sazakli et al. (2014) | Blood collected from people exposed to Cr(VI) in drinking water | ↑ IL-12, dose dependent; No effect on IL-6, IL-8, or IL-10
Snyder et al. (1996) | Blood collected from people exposed to Cr(VI) environmentally in Hudson County, New Jersey | ↓ IL-6
Qian et al. (2013) | Serum collected from Cr(VI)-exposed workers | ↓ IL-6, IL-10, IL-17A, IFN-γ, and IFN-γ/IL-4; No effect on IL-2 or TNF-α
Mignini et al. (2009) | Plasma collected from Cr(VI)-exposed workers | ↑ IL-2 and IL-6; ↓ IL-12; No change in IL-1β, IL-4, TNF-α, or IFN-γ
Mitrov et al. (2014) | Plasma collected from rats exposed to Cr(VI) | ↑ IL-1β and TNF-α
Jin et al. (2016) | Serum from LPS-stimulated mice exposed to Cr(VI) | ↑ IL-6 and TNF-α
Thompson et al. (2012c) | Plasma from Cr(VI)-exposed rats | ↓ IL-12 and CXCL10 (IP-10); No effect on IL-1α, IL-1β, IL-2, IL-4, IL-5, IL-6, IL-10, IL-13, IL-17, IL-18, TNF-α, IFN-γ, CCL5, CXCL1, Eotaxin, G-CSF, GM-CSF, MCP-1, or MIP-1α
Thompson et al. (2011b) | Plasma from Cr(VI)-exposed mice | “Few cytokines exhibited significant changes” but no specific data; tested IL-1α, IL-1β, IL-2, IL-4, IL-5, IL-6, IL-7, IL-9, IL-10, IL-12, IL-13, IL-15, IL-17, TNF-α, IFN-γ, CXCL1, CCL5, CXCL10, G-CSF, GM-CSF, MCP-1, and MIP-1α
Cytokines measured in BALF
Cohen et al. (2010) | BALF from Cr(VI)-exposed rats | No effect on TNF-α, MIP-2, MCP-1, IL-6, IL-10, or IL-12
Cytokines secreted by MoDC
Reutter et al. (1997) | Human MoDC exposed to Cr(VI) in vitro | ↑ IL-1β
Toebak et al. (2006) | Human MoDC exposed to Cr(VI) in vitro | No effect on IL-8, CCL5, CCL17, CCL18, CCL20, and CCL22
Cytokines secretion by stimulated PBMCs, lymphocytes, splenocytes, and macrophages
Akbar et al. (2011) | Stimulated (anti-CD3 or anti-CD3/anti-CD28) primary human lymphocytes | ↓ IL-2 and IFN-γ
Ban et al. (2010) | ConA-stimulated lymph nodes collected from mice | ↓ IL-4 (NS), IL-5 (NS), and IL-13 (NS); ↑ IFN-γ (NS)
Cohen et al. (1998) | Pulmonary macrophages collected from Cr(VI) exposed rats, stimulated with LPS ex vivo | ↓ IL-1, TNF-α, and IL-6 (NS)
Dai et al. (2017b) | Stimulated (anti-CD3/anti-CD28) splenic lymphocytes collected from Cr(VI)-exposed mice | ↓ IL-2, IL-4, and IL-10
Katiyar et al. (2008) | PHA and LPS-stimulated PBMCs collected from exposed workers | ↑ PHA-stimulated IL-2 (NS) production; ↑ PHA-stimulated IL-6 production; No effect on LPS-stimulated TNF-α production
Karaulov et al. (2019) | Mitogen-stimulated (ConA) splenocytes collected from rats | ↑ IL-4 and IL-10 (NS); ↓ IL-6; No effect on INF-γ
Cytokines secretion by unstimulated PBMCs
Lindemann et al. (2008) | PBMCs collected from chromium sensitized workers and exposed to Cr(VI) in vitro | ↑ IL-4, IL-10, and IFN-γ; No effect on IL-2 or IL-12
Cytokines secretion by peritoneal macrophages
Christensen et al. (1992) | Newcastle disease virus infected mouse peritoneal macrophages exposed to Cr(VI) in vitro | ↓ IFN-α/β
Jin et al. (2016) | Mouse peritoneal macrophages | ↑ IL-1α, IL-1β, IL-6, and TNF-α
Cytokines secretion by cell cultures
Adam et al. (2017) | TPA stimulated THP-1 cells | ↑ IL-1β
Badding et al. (2014)) | RAW264.7 cells exposed to Cr(VI) | ↑ TNF-α (NS); No effect on IL-6 or IL-1β
Ban et al. (2010) | Spleens collected from mice | ↓ IL-4, IL-5, IL-13, and IFN-γ
Jin et al. (2016) | Serum from LPS-stimulated RAW264.7 cells exposed to Cr(VI) | ↑ IL-6 and TNF-α
Cytokines secreted by HaCaT cultures
Wang et al. (2010a) | Human HaCaT cells treated with Cr(VI) | ↑ IL-1α and TNF-α
Lee et al. (2014) | Human HaCaT cells treated with Cr(VI) | ↑ IL-1α and TNF-α
Cytokines secreted by duodenum
Thompson et al. (2012c) | Duodenum from Cr(VI)-exposed rats | ↑ IL-1α; ↓ IL-4; ↑ IL-6 (60 mg/L SDD); No effect on IL-1β, IL-2, IL-5, IL-10, IL-12, IL-13, IL-17, IL-18, TNF-α, IFN-γ, CCL5, CXCL1, CXCL10, Eotaxin, G-CSF, GM-CSF, MCP-1, or MIP-1α
Thompson et al. (2011b) | Duodenum from Cr(VI)-exposed mice | ↓ IL-1β and TNF-α, dose-dependent trends; For all other cytokines, no specific data were reported, other than “Several cytokines were significantly altered—generally beginning at 60 mg/L SDD”; tested IL-1α, IL-2, IL-4, IL-5, IL-6, IL-7, IL-9, IL-10, IL-12, IL-13, IL-15, IL-17, IFN-γ, CXCL1, CCL5, CXCL10, G-CSF, GM-CSF, MCP-1, and MIP-1α
Cytokines secreted by oral mucosa
Thompson et al. (2012c) | Oral mucosa from Cr(VI)-exposed rats | No effect on IL-1α, IL-1β, IL-2, IL-4, IL-5, IL-6, IL-10, IL-12, IL-13, IL-17, IL-18, TNF-α, IFN-γ, CCL5, CXCL1, CXCL10, Eotaxin, G-CSF, GM-CSF, MCP-1, or MIP-1α
Thompson et al. (2011b) | Oral mucosa from Cr(VI)-exposed mice | “Significant differences from control animals were generally limited to the highest treatment dose,” but no specific data; tested IL-1α, IL-1β, IL-2, IL-4, IL-5, IL-6, IL-7, IL-9, IL-10, IL-12, IL-13, IL-15, IL-17, TNF-α, IFN-γ, CXCL1, CCL5, CXCL10, G-CSF, GM-CSF, MCP-1, and MIP-1α

NS = not statistically significant, BALF = bronchoalveolar lavage fluid, ConA = concanavalin A; HaCaT cells = immortalized human keratinocytes; LPS = lipopolysaccharide; MoDC = monocyte-derived dendritic cell; PBMC = peripheral blood mononuclear cell; TPA = 12-O-tetradecanoylphorbol-13-acetate.

### C.2.6 Male Reproductive Effects

#### C.2.6.1 Mechanistic studies relevant to male reproductive toxicity

Mechanistic evidence indicating the biological pathways involved in male reproductive toxicity following Cr(VI) exposure is summarized in Table C-39. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “reproductive” if they involved reproductive tissues or cells; 49 studies were identified. Studies were prioritized for consideration in the synthesis of mechanistic evidence for male reproductive effects if they were conducted in mammalian species:

- Studies in humans with quantified oral or inhalation exposure to Cr(VI)
- Studies in experimental animals with quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation, or injection exposure to Cr(VI)
- In vitro studies in primary or immortalized mammalian cells derived from male reproductive tissues (i.e., Leydig, Sertoli, male germ cells)
- Mechanistic endpoints relevant to interpretations of male reproductive health effects in humans

A total of 25 reproductive studies were identified to include in the male reproductive mechanistic synthesis. Several of the included oral exposure animal toxicological studies in that section were identified as also reporting mechanistically relevant data, as well as i.p. injection studies that did not meet PECO criteria but were reviewed as being potentially relevant for mechanistic analysis. In vitro studies that evaluated Leydig, Sertoli, or male germ cells were also considered for mechanistic evidence.

Table C-39 Mechanistic studies prioritized for informing potential Cr(VI)-induced male reproductive toxicity

System | Route | Exposure^a^ | Results | Reference
Oxidative stress
Mouse, male (strain not reported) | Oral (not specified) | 5 mg/kg-d K_2_Cr_2_O_7_, 30- or 60 d | ↓ serum antioxidant enzymes (CAT, SOD, GPx); ↑ serum MDA | Rasool et al. (2014)
Rat, Sprague-Dawley, male | Oral (inferred to be gavage) | 10 mg/kg-d [form of Cr(VI) not reported], 13 d | ↓ testicular and epididymal CAT, SOD, GST, glutathione; ↑ testicular and epididymal MDA | Kim et al. (2012)
Monkey, bonnet, male | Oral (drinking water) | 100, 200, 400 mg/L K_2_Cr_2_O_7_, 180 d | ↓ testicular SOD, CAT, GPx, GR, G-6-PDH, γ-GT, and vitamins A, C, E; ↑ testicular GST and reduced glutathione; ↑ testicular H_2_O_2_ and OH– | Aruldhas et al. (2005)
Monkey, bonnet, male | Oral (drinking water) | 50, 100, 200, 400 mg/L K_2_Cr_2_O_7_, 6 mo | ↓ SOD, and GDH in seminal plasma and sperm; ↑ H_2_O_2_ in seminal plasma and sperm | Subramanian et al. (2006)
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14 or GD 15–21; F1 animals evaluated on PND 30 | ↑ lipid peroxidation, H_2_O_2_, OH– in Sertoli cells; ↑ SOD, CAT, GPx, GSR, GST, and GSH in Sertoli cells | Shobana et al. (2020)
Rat, Wistar, male | Oral (gavage) | 3.5 mg/kg-d Cr(VI), 8 wk | ↑ testicular MDA, GSSG, NO; ↓ testicular GSH, SOD, CAT, carnitine; Mitigated by cotreatment with antioxidant | Bashandy et al. (2021)
Mouse, Swiss albino, male | i.p. injection | 1 mg/kg CrO_3_, single injection | ↓ testicular SOD, CAT, peroxidase; ↑ testicular lipid peroxidation potential | Acharya et al. (2006)
Rat, Wistar, male | i.p. injection | 1–2 mg/kg-d K_2_Cr_2_O_7_, 15 d | ↓ testicular CAT; ↑ testicular metallothionein; ↑ testicular MDA, O_2_– | Marouani et al. (2015a)
Rat, Wistar, male | i.p. injection | 10 mg/kg-d Na_2_Cr_2_O_7_, 10 d | ↓ testicular SOD, CAT, GPx; ↑ testicular MDA; Mitigated by cotreatment with antioxidant | Hfaiedh et al. (2014)
Rat, Wistar, male | i.p. injection | 2mg/kg-d, K_2_Cr_2_O_7_, 21 d | ↑ testicular indicators of lipid peroxidation (TBARS and H_2_O_2_) with significant effect decrease with antioxidant pretreatment; ↓ testicular GSH and activity antioxidant, phosphatase, and aminotransferase mitigated by antioxidant pretreatment | El-Demerdash et al. (2019)
Mouse, Swiss albino, male | i.p. injection | 10 mg/kg CrO_3_, single dose with evaluation 5,6,7, and 8 wk after treatment (control 5 wk only) | ↑ testicular indicators of lipid peroxidation (TBARS) | Acharya et al. (2004b)
Cultured mouse Leydig cells (TM3), Sertoli cells (TM4), and spermatogonial stem cells | In vitro | 3.125–50 μM Cr(VI) | ↑ ROS after 4 hr; ↓ mRNA expression of antioxidant enzymes (Sod, Cat, Gpx1, Gsta4) after 24 hr; ↑ mRNA expression of Gsta1 at all doses in somatic cells and low doses in germ cells after 24 hr | Das et al. (2015)
Cultured mouse spermatogonial stem cells (C18-4) | In vitro | 5–75 μM Cr(VI) | ↑ ROS after 24 hr | Lv et al. (2018)
Cell cycle regulation and apoptosis in somatic and germ cells
Rat, Wistar, male | Oral (gavage) | 3.5 mg/kg-d Cr(VI), 8 wk | ↑ p53 expression in spermatogenic cells; ↓ DNA content of spermatogenic cells; Mitigated by cotreatment with antioxidant (melatonin) | Bashandy et al. (2021)
Rat, Wistar, male | i.p. injection | 1–2 mg/kg-d K_2_Cr_2_O_7_, 15 d | ↑ BAX and DNA fragments in testis | Marouani et al. (2015a)
Mouse, ICR, male | i.p. injection | 16.2 mg/kg-d Cr(VI), 1 wk | ↑ BAX and DNA fragments (γ-H2AX) in testis; Qualitative histopathology showing degenerative changes in seminiferous tubules and germ cells; Cr(VI) treated males also had decreased litter sizes; Mitigated by cotreatment with antioxidant (melatonin) | Lv et al. (2018)
Rat, Wistar, male | i.p. injection | 2mg/kg-d, K_2_Cr_2_O_7_, 21 d | Qualitative histopathology showed degeneration of spermatogenic cells in testes and moderate atrophy | El-Demerdash et al. (2019)
Mouse, Swiss albino, male | i.p. injection | 10 mg/kg CrO_3_, single dose with evaluation 5,6,7, and 8 wk after treatment (control 5 wk only) | ↓ sperm count at all timepoints; ↑ sperm abnormalities at all timepoints | Acharya et al. (2004b)
Rabbit, ITRC colony, male | i.p. injection | 2mg/kg-d, K_2_Cr_2_O_7_, evaluation at 3 and 6 wk 72 hr after last injection | Qualitative histological analysis, progressive testicular interstitial edema, no spermatocytes in seminiferous tubules | Behari et al. (1978)
Cultured mouse Leydig cells (TM3), Sertoli cells (TM4), and spermatogonial stem cells | In vitro | 3.125–50 μM Cr(VI) | ↑ TUNEL-positive cells; ↓ mitochondrial membrane potential; ↑ biomarkers of intrinsic apoptosis (e.g., cleavage of caspases 3 and 9, ↓ BCL2/BAX ratio); ↓ biomarkers of extrinsic apoptosis (Fas, caspase 8) in somatic cells; Mitigated by cotreatment with antioxidant (N-acetyl-L-cysteine) | Das et al. (2015)
Cultured mouse spermatogonial stem cells (C18-4) | In vitro | 5–75 μM Cr(VI) | ↑ TUNEL-positive cells; ↑ DNA fragments (γ-H2AX); ↑ chromatin condensation; ↑ biomarkers of intrinsic apoptosis (e.g., cleavage of caspases 3 and 9, ↑ BAX, ↓ BCL-2); Mitigated by cotreatment with antioxidant (melatonin); No effect on biomarkers of extrinsic apoptosis (caspase 8); (after 24 h) | Lv et al. (2018)
Primary coculture of rat (Wistar); Sertoli cells and germ cells | In vitro | 0.5, 1, 10, 100 μg/L Cr(VI) | ↓ late spermatocytes and round spermatids; ↑ cells with alterations in meiotic prophase; ↑ asynapsis and fragmented synaptonemal complexes | Geoffroy-Siraudin et al. (2010)
Altered steroidogenesis and effects on the hypothalamic-pituitary-gonadal axis
Rat, Sprague-Dawley F1, male | Oral (gavage) | 3–12 mg/kg-d Cr(VI), GD 12–21; F1 animals evaluated on PND 21 | Biphasic effect on testosterone (↑ at low dose, ↓ at high dose); Biphasic mRNA and protein expression of LHR (↑ at low dose, ↓ at high dose); ↑ low dose expression of FSHR (mRNA only), SCARB1, LIF, PDGFA (no change at high dose); ↓ high dose expression of IGF1, CYP17A1 (protein only), HSD17B3 (mRNA only), StAR (protein only, not significant); No change in mRNA or protein expression of CYP11A1, insulin-like-3 hormone, NR5A1, SOX9, AMH, DHH | Zheng et al. (2018)
Rat, Wistar, male | Oral (gavage) | 3.5 mg/kg-d Cr(VI) | ↓ plasma testosterone, LH; ↑ FSH; Mitigated by cotreatment with antioxidant | Bashandy et al. (2021)
Rabbit, New Zealand white, male | Oral (gavage) | 3.6 mg/kg-d Cr(VI), 10 wk | ↓ plasma testosterone | Yousef et al. (2006)
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14, F1 animals evaluated on PND 60 | ↓ serum testosterone, prolactin; ↑ serum estrogen, LH, FSH; ↓ protein expression of AR, LHR, PRLR, and ERα in Leydig cells; ↑ protein expression of ERβ in Leydig cells; ↓ protein expression of StAR, CYP11A1, 3βHSD, CYP17A1, 17βHSD, 5α reductase, aromatase in Leydig cells; ↓ specific activities of 3βHSD and 17βHSD in Leydig cells; ↓ protein expression of AR, FSHR, ERα, ERβ, and 5α reductase in Sertoli cells | Navin et al. (2021)
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14 or GD 15–21, F1 animals evaluated on PND 30 | ↓ serum testosterone, prolactin; ↑ serum estrogen, LH, FSH; ↓ mRNA and protein expression of AR and FSHR in Sertoli cells; ↓ protein expression of transcriptional regulators of Fshr (USF-1, USF-2, GATA-1, c-jun, c-fos) and Ar (Sp-1, ARA54, CBP, SRC-1) in Sertoli cells; ↑ protein expression of cyclin D1 and p53 (inhibitors of Ar expression); ↓ mRNA expression of Ar and Fshr in Sertoli cells | Shobana et al. (2020)
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14; F1 animals evaluated on PND 120 | ↓ testosterone in serum and testicular interstitial fluid; ↓ serum FSH and LH; ↓ gene and protein expression of AR and FSHR in Sertoli cells | Kumar et al. (2017)
Rat, Wistar, male | Oral (drinking water) | K_2_Cr_2_O_7_, 500 mg/L in drinking water [estimated to be 73.05 mg/kg-d Cr(VI)], 30 d | ↓ serum prolactin (60% of control); No change in serum LH accumulation of Cr in target tissues (pituitary, hypothalamus, liver). 30% reduction in water intake and 11.6% reduction in BW. Study also includes in vitro study in primary anterior pituitary cells (see later in table). | Quinteros et al. (2007)
Rat, Wistar, male | Oral (drinking water) | K_2_Cr_2_O_7_, 200 mg/L in drinking water [estimated to be 11.6 mg/kg-d Cr(VI)], 30 d | ↑ Lipid peroxidation in pituitary and hypothalamus; no change in liver.; ↑ SOD activity in pituitary only; ↑ CAT activity in liver only; ↑ glutathione reductase activity in hypothalamus only; No changes in GPx activity; ↑ in HO-1 mRNA expression in hypothalamus and pituitary only; ↑ MT-3 in hypothalamus and MT-1 in anterior pituitary; Accumulation of Cr in target tissues (pituitary, hypothalamus, liver). No significant change in water consumption or BW. Did not measure if oxidative effects impacted downstream hormones. | Nudler et al. (2009)
Rat, Wistar, male | i.p. injection | 2mg/kg-d, K_2_Cr_2_O_7_, 21 d | ↓ serum testosterone; ↑ serum FSH; Mitigated by cotreatment with antioxidant | El-Demerdash et al. (2019)
Rat, Wistar, male | i.p. injection | 1–2 mg/kg-d K_2_Cr_2_O_7_, 15 d | ↓ serum testosterone and LH; ↑ serum FSH | Marouani et al. (2012)
Rat, Wistar, male | i.p. injection | 10 mg/kg-d Na_2_Cr_2_O_7_, 10 d | ↓ serum testosterone; Mitigated by cotreatment with antioxidant | Hfaiedh et al. (2014)
Cultured mouse Leydig cells (TM3) and Sertoli cells (TM4) | In vitro | 6.25–25 μM Cr(VI) | ↓ testosterone secretion by TM3 cells; ↓ mRNA expression of steroidogenic enzymes (Cyp11a1, Hsd3b1, Cyp17a1, Cyp19a1) in TM3 cells; ↓ mRNA expression of Fshr, Ar in TM4 cells; ↑ mRNA expression of Star in TM3 cells | Das et al. (2015)
Primary anterior pituitary cells from male Wistar rat | In vitro | K_2_Cr_2_O_7_, 0.1–10 μM up to 72 hr | ↓ prolactin at 0.1 μM at 72 hr, 1 and 10 μM at 48 hr and 72 hr; No change in LH; ↑ Caspase 3 and 10 μM [cytotoxic, prevented pretreatment with an antioxidant (NAC)]; Same study that showed decreased prolactin and no change in LH in vivo (see earlier in table). Cell viability significantly reduced after 24 hr at 10 μM (~65%); 1 μM after 72 hr. | Quinteros et al. (2007)
Primary anterior pituitary cells from male Wistar rat | In vitro | K_2_Cr_2_O_7_, 10 μM for 72 hr | Mechanisms involved in apoptosis include decreased CAT, GPx, increased p53 and Bax Data not fully reviewed because cytotoxic concentration was used, as demonstrated in Quinteros et al. (2007) | Quinteros et al. (2008)
Effects on Sertoli cells and the blood-testis barrier
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14 or GD 15–21, F1 animals evaluated on PND 30 | ↓ secretory products of Sertoli cells (inhibin, androgen binding protein, transferrin, lactate, pyruvate, retinoic acid); ↓ mRNA and protein expression of tight junction proteins (claudin-11 and occludin) in Sertoli cells | Shobana et al. (2020)
Rat, Wistar F1, male | Oral (drinking water) | 50–200 mg/L K_2_Cr_2_O_7_, GD 9–14, F1 animals evaluated on PND 120 | ↓ mRNA and protein expression of tight junction proteins (claudin-11 and occludin) in Sertoli cells | Kumar et al. (2017)
Rat, Druckrey, male | i.p. injection | 2 mg/kg-d K_2_Cr_2_O_7_, 15-d | Leakage of Sertoli cell tight junctions and adverse effects on late-stage spermatids | Murthy et al. (1991) ^b^
Mouse Sertoli cells (TM3) | In vitro | 6.25–25 μM Cr(VI) | ↓ mRNA expression of tight junction signaling molecules (tight junction protein 1, vimentin, occludin) | Das et al. (2015)
Primary coculture of rat (Sprague-Dawley) Sertoli cells and germ cells | In vitro | 10 μg/L Cr(VI) | ↓ gap junction signaling and delocalization of connexin 43 from the membrane to the cytoplasm after 8 d; no effects on adherin or tight junction proteins (claudin-11 and N-cadherin); ↑ transepithelial resistance | Carette et al. (2013)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

b Note: Scientific integrity is a concern due to evidence of self-plagiarism within this research group.

### C.2.7 Female Reproductive Effects

#### C.2.7.1 Mechanistic studies relevant to female reproductive toxicity

Mechanistic evidence indicating the biological pathways involved in female reproductive toxicity following Cr(VI) exposure is summarized in Table C-40. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “reproductive” if they involved reproductive tissues or cells. Studies were prioritized for consideration in the synthesis of mechanistic evidence for female reproductive effects if they were conducted in mammalian species:

- Studies in humans with quantified oral or inhalation exposure to Cr(VI)
- Studies in experimental animals with quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation, or injection exposure to Cr(VI)
- In vitro studies in primary or immortalized mammalian cells derived from female reproductive tissues (e.g., thecal and granulosa cells)
- Mechanistic endpoints relevant to interpretations of female reproductive health effects in humans

A total of 12 reproductive studies were identified to include in the female reproductive mechanistic synthesis. Several of the included oral exposure animal toxicological studies in that section were identified as also reporting mechanistically relevant data, as well as i.p. injection studies that did not meet PECO criteria but were reviewed as being potentially relevant for mechanistic analysis. In vitro studies conducted in relevant cell types, such as thecal and granulosa cells, were also considered for mechanistic evidence.

Table C-40 Mechanistic studies prioritized for informing potential Cr(VI)-induced female reproductive toxicity

System | Route | Exposure^a^ | Results | Reference
Altered steroidogenesis
Rat, lactating Sprague-Dawley | Oral (drinking water) | 50, 100, 200 mg/L K_2_Cr_2_O_7_, PNDs 1–21; F1 animals evaluated on PNDs 25, 45, 65 | For F1:; ↓ FSH receptor gene expression in ovary; ↓ E2, T, P4 (dose dependent, in hormone section of animal tox); ↑ FSH (not dose dependent); Mitigated by cotreatment with vitamin C | Stanley et al. (2013)
Rat, lactating Sprague-Dawley | Oral (drinking water) | 5, 10, 25, 50, 100, and 200 mg/L K_2_Cr_2_O_7_, PNDs 1–21; F1 animals evaluated on PNDs 25, 45, 65 | For F1:; ↓ E2, T, P4 (50 mg/L, PND 25); ↑ time to puberty (50 mg/L); Cotreatment with estradiol restored the ovarian protein expression of several antioxidant enzymes (Gpx1, catalase, Prdx3, and Txn2) | Stanley et al. (2014)
Rat, lactating Sprague-Dawley | Oral (drinking water) | 50 mg/L K_2_Cr_2_O_7_, PNDs 1–21; F1 animals evaluated on PND 25 | For F1:; ↓ ovarian expression of steroidogenic acute regulator protein (StAR), 3β-hydroxysteroid dehydrogenase, and aromatase; ↑ genes involved in the metabolic clearance of estradiol (Cyp1a1, Cyp1b1, UDP-glucuronosyltransferases, Sult1a1, NAD(P)H quinone oxidoreductase l); Mitigated by cotreatment with resveratrol | Banu et al. (2016)
Rat, Wistar, female, GDs 9–21; female pups PND 65 | Oral (drinking water) | Group 1: 50, 100, 200, and 400 mg/L K_2_Cr_2_O_7_, GDs 9–21; F1 animals evaluated on PND 0; Group 2: 200 mg/L K_2_Cr_2_O_7_, GDs 9–PND 65; F1 animals evaluated on PNDs 0, 3, 7, 18, 45, 65 | For F1:; ↓ serum progesterone, estradiol, testosterone, prolactin, growth hormone; ↑ serum LH and FSH | Samuel et al. (2012)
Primary rat granulosa cells | In vitro | 10 μM K_2_Cr_2_O_7_, 12 or 24 hr | ↓ FSH receptor protein expression; Pretreatment with vitamin C mitigated | Stanley et al. (2013)
Primary Sprague-Dawley rat granulosa cells (immature rats, 23–25 d old); immortalized rat granulosa cells | In vitro | 10 μM K_2_Cr_2_O_7_, 12 or 24 hr | ↓ Erβ and FSH receptor gene expression; Pretreatment with vitamin C mitigated | Stanley et al. (2011)
Immortalized rat granulosa cells | In vitro | 12.5 μM K_2_Cr_2_O_7_, 12 and 24 hr | ↓ gene expression of FSH receptor, LH receptor, Erα, Erβ, StAR, SF-1 (24 hr only), and 17β-hydroxysteroid dehydrogenases; ↓ cell proliferation 50% | Banu et al. (2008)
Oxidative stress
Rat, lactating Sprague-Dawley | Oral (drinking water) | 50, 100, 200 mg/L K_2_Cr_2_O_7_ (2013); 5, 10, 25, 50, 100, and 200 mg/L K_2_Cr_2_O_7_ (2014); PND 1–21; F1 animals evaluated on PND 25 (2014) or PNDs 25, 45, 65 (2013) | For F1:; ↓ ovarian SOD, catalase, glutathione peroxidase, and glutathione reductase activity (100 mg/L 2013; 50 mg/L, 2014); ↓ ovarian protein expression of GPx1, Txn2, Prdx3, CAT expression (2014); ↑ ovarian protein expression of glutathione-S-transferase (2013); ↑ ovarian LPO, H_2_O_2_ (dose dependent 2013; 50 mg/L, 2014); Mitigated by cotreatment with VitC (2013) or EDA (2014) | Stanley et al. (2013); (2014)
Rat, strain not reported (assume Sprague-Dawley) | Oral (drinking water) | 25 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5; F1 animals evaluated on PND 1 | For F1:; ↑ p53/SOD2 protein colocalization in the ovary; p53 has been demonstrated to reduce SOD2 antioxidant activity | Sivakumar et al. (2014)
Rat, lactating Sprague-Dawley | Oral (drinking water) | 50 mg/L K_2_Cr_2_O_7_, PND 1–21; F1 animals evaluated on PND 25 | For F1:; ↓ ovarian protein expression of catalase, glutathione peroxidase (GPx1), peroxiredoxin (PRDX) 3, and thioredoxin (TXN).; ↑ ovarian protein expression of SOD1 and SOD2; ↑ oxidative damage in ovary (LPO, H_2_O_2_); Oxidative damage mitigated by cotreatment with resveratrol | Banu et al. (2016)
Mouse, Swiss albino, female | Oral (gavage) | 5 and 10 mg K_2_Cr_2_O_7_/kg, 30-d | ↑ Lipid peroxidation in ovary (MDA); ↓ ovarian SOD and CAT activity, and ↓ levels of vitamin C and glutathione (dose-dependent); Mitigated by cotreatment with vitamin E | Rao et al. (2009)
Rat, Wistar, female, GD 9–21; female pups PND 65 | Oral (drinking water) | Group 1: 50, 100, 200, and 400 mg/L K_2_Cr_2_O_7_, GDs 9–21; F1 animals evaluated on PND 0; Group 2: 200 mg/L K_2_Cr_2_O_7_, GD 9–PND 65; F1 animals evaluated on PNDs 0, 3, 7, 18, 45, 65 | For F1:; ↓ ovarian SOD, CAT, GPx activity; ↓ ovarian ascorbic acid; ↑ ovarian LPO and H_2_O_2_ at all ages | Samuel et al. (2012)
Rat, Wistar, female | i.p. injection | 1 and 2 mg K_2_Cr_2_O_7_/kg, 15-d | ↑ Superoxide anion in uterus (as measured by cytochrome C and iodonitrotetrazolium reduction); ↓ CAT activity in uterus; ↑ lipid peroxidation in uterus; ↓ metallothionine; All dose dependent | Marouani et al. (2015b)
Primary rat granulosa and theca cells; immortalized rat granulosa cells | In vitro | 10 μM K_2_Cr_2_O_7_, 12 hr and 24 hr | ↓ intracellular vitamin C levels; ↓ SOD1, SOD2, CAT, GLRX1, GSTM1, GSTM2, GSTA, GR, TXN1, TXN2, TXNRD2, and PRDX3 gene expression (time dependent); ↓ GR, GST, GPx, SOD, CAT activity; ↑ H_2_O_2_, LPO; Immortalized GCs showed similar effect.; Cell viability not reported. Vitamin C failed to mitigate CrVI effects on GSTM1, GSTM2, TXN1, and TXN2 in TCs | Stanley et al. (2013)
Apoptosis
Rat, lactating Sprague-Dawley | Oral (drinking water) | 50 mg/L K_2_Cr_2_O_7_, PNDs 1–21; F1 animals evaluated on PND 25 | For F1:; ↑ follicular cell apoptosis (TUNEL); ↑ ovarian protein expression of cytochrome C, caspase-3; ↓ ovarian protein expression of Bcl-2, Bcl-XL, HIF-1α; Mitigated by cotreatment with resveratrol | Banu et al. (2016)
Rat, pregnant Sprague-Dawley | Oral (drinking water) | 25 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5; F1 animals evaluated on GDs 15.5 and 17.5, PNDs 1, 4, 25 | For F1:; ↑ germ cell apoptosis (TUNEL) | Banu et al. (2015)
Rat, lactating Sprague-Dawley | Oral (drinking water) | 5, 10, 25, 50, 100, and 200 mg/L K_2_Cr_2_O_7_ (2014); 50, 100, 200 mg/L K_2_Cr_2_O_7_ (2013); PNDs 1–21; F1 animals evaluated on PND 25 (2014) or PNDs 25, 45, 65 (2013) | For F1:; ↑ dose-dependent follicular (granulosa) cell apoptosis (TUNEL) and atretic %; ↑ ovarian protein expression of caspase-3 (50 mg/L, 2014); ↓ ovarian protein expression of Bcl-2, Bcl2l1 (50 mg/L, 2014); granulosa and theca cells with 50 mg/L were 50% positive PND 25 (2013). 5 mg/L were 30% positive PDN 25 (2014) | Stanley et al. (2013); Stanley et al. (2014)
Rat, pregnant Sprague-Dawley | Oral (drinking water) | 10 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5; F1 animals evaluated on PND 1 | For F1:; ↑ germ cell apoptosis (TUNEL); ↑ ovarian protein expression of acetyl-p53, cleaved caspase-3, BAX, PUMA; ↓ ovarian protein expression of Bcl-2, Bcl-XL, p-AKT; Effects other than p-AKT were exacerbated by SIRT1 inhibitor | Sivakumar et al. (2022)
Rat, strain not reported (assume Sprague-Dawley) | Oral (drinking water) | 25 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5; F1 animals evaluated on PND 1 | For F1:; ↑ germ cell apoptosis (TUNEL); ↑ ovarian protein expression of BAX, caspase 3, p53, p27; ↓ ovarian protein expression of p-AKT, p-ERK, and XIAP | Sivakumar et al. (2014)
Rat, Wistar, female | i.p. injection | 1 and 2 mg K_2_Cr_2_O_7_/kg, 15-d | ↓ relative ovary/uterine weight (with decreased bw; 40% and 137% of controls, dose dependent); ↑ apoptotic cells and protein expression of Bax in uterus; Uterine Bcl-2 was not detected in control or Cr(VI) treatment groups; Apoptosis was characterized by chromatin condensation, detected by borated toluidine blue staining; Bax/Bcl-2 by immunostaining | Marouani et al. (2015b)
Primary Sprague-Dawley rat granulosa cells (immature rats, 22–25 d old) | In vitro | 10 μM K_2_Cr_2_O_7_, 12 or 24 hr | ↑ apoptosis; ↑ translocation of cytochrome C from mitochondria to cytosol, ↑ cleaved caspase-3 and PARP (important terminal events in apoptosis); ↑ Bax, t-Bad; ↓ Bcl-2, Bcl-XL, pBad-112/136, Hsp-70, Hsp-90; ↑ p-ERK, p-JNK; ↓ p-AKT; no change in p-p38 (indicates suppression of AKT pathway but activation of ERK1/2 pathway); ↑ p53 (total and phosphorylated at specific serine sites); higher in mitochondria compared with cytosol, suggesting translocation to the mitochondria.; ↓ apoptosis after cotreatment with ERK1/2 and JNK inhibitor; ↓ p53 activity after cotreatment with ERK1/2 inhibitor; no effect of JNK inhibitor; ↑ p-ERK in mitochondria and nucleus Mitigated by pretreatment with vitamin C | Banu et al. (2011)
Primary Sprague-Dawley rat granulosa cells (immature rats, 23–25 d old); immortalized rat granulosa cells | In vitro | 10 μM K_2_Cr_2_O_7_, 12 or 24 hr | Cell cycle arrest at G1 phase (decreased cell population at S and G2-M phases); ↓ protein expression of cyclin-dependent kinases 1, 2, 4, 6 in both cell types; cyclins D2&3, E2, B1; PCNA; ↑ protein expression of p15, p16, p27; Results time dependent; Mitigated by pretreatment with vitamin C | Stanley et al. (2011)
Ovarian extracellular matrix
Rat, pregnant Sprague-Dawley | Oral (drinking water) | 25 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5; F1 animals evaluated on GDs 15.5 and 17.5, PNDs 1, 4, 25 | For F1:; ↑ ovarian protein expression of Xpnpep2 and ↓ collagen (Col1, Col3, Col4) in fetuses; ↓ ovarian protein expression of Xpnpep2 and ↑ collagen (Col1, Col3, Col4) in pups at PNDs 1, 4, and 25; Protein expression of Xpnpep2 and collagens measured using immunohistochemistry | Banu et al. (2015)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.2.8 Developmental Effects

#### C.2.8.1 Mechanistic studies relevant to developmental toxicity

Mechanistic evidence indicating the biological pathways involved in developmental toxicity following Cr(VI) exposure is summarized in Table C-41. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “developmental” if they involved embryonic development or survival. The following studies were prioritized:

- Studies in humans with quantified oral or inhalation exposure to Cr(VI)
- Studies in experimental animals with quantified oral (drinking water, gavage, diet), inhalation, or intratracheal instillation, or injection exposure to Cr(VI)
- In vitro studies in primary or immortalized mammalian cells derived from tissues relevant to mammalian development, including embryonic and placental tissues and cells and cells involved in organ development (e.g., osteoblasts)
- Mechanistic endpoints relevant to interpretations of effects on human development, including genotoxicity tests relevant to fetal development (e.g., rodent dominant lethal test)

A total of 14 developmental studies were identified to include in the developmental toxicity mechanistic synthesis. Studies were prioritized for consideration in the synthesis of mechanistic evidence for developmental effects if they were conducted in mammalian species. Several of the included oral exposure animal toxicological studies in that section were identified as also reporting mechanistically relevant data, as well as i.p. injection studies that did not meet PECO criteria but were reviewed as being potentially relevant for mechanistic analysis. In vitro studies conducted in relevant cell types derived from tissues relevant to mammalian development were also considered for mechanistic evidence. In vitro studies in human trophoblasts or mitochondria isolated from human placentas were considered as potentially relevant to effects in the placenta, and studies in osteoblasts were also considered as potentially relevant for the evaluation of skeletal effects. Effects are also expected to be more likely in in vitro embryonic studies compared with in vivo studies, as the in vitro studies incubated sperm or blastocytes directly with potassium dichromate.

Table C-41 Mechanistic studies prioritized for informing potential Cr(VI)-induced developmental toxicity

System | Route | Exposure^a^ | Results | Reference
Fetal genotoxicity
Mouse, pregnant Swiss albino | Oral (drinking water) or i.p. injection | Drinking water study: 1.7 and 3.5 mg/L K_2_Cr_2_O_7_, duration of pregnancy; i.p. study: 17.7 mg/kg Na_2_Cr_2_O_7_ or K_2_Cr_2_O_7_, single dose on GD 17; Euthanasia on GD 18 | ↑ significant increase in micronucleated polychromatic erythrocytes in maternal bone marrow, fetal liver, and fetal peripheral blood after i.p. injection.; No effects after oral dosing. | De Flora et al. (2006)
In vitro evaluations of embryo development
Dub:(ICR) mouse blastocysts from d 4 of gestation with 6 d of exposure or embryos from d 8 for 24 hr | In vitro | 0.25–2 μM K_2_Cr_2_O_7_ | ↑ blastocyst (1 and 2 μM) and embryo (all concentrations) SCEs; No effects on embryo hatching, attachment of trophoblast outgrowth; ↓ blastocyst inner cell masses; ↓ embryo development including crown-rump length | Iijima et al. (1983)
Sperm and untreated oocytes from BDF1 mice | In vitro | 3.125, 6.25, 12.5, 25, or 50 μM K_2_Cr_2_O_7_ | ↓ acrosome reaction (12.5 μM+); ↑ time to expanded and hatching blastocyst stage; ↓ blastocyst ICM and TE cell proliferation; ↓ ICM-TE expression sox2, pou5f1, klf4 all conc; cdx2 at 12.5 μM; eomes and krt8 at 25 μM (all pluripotent marker genes); Sperm viability was significantly decreased at 6.25 μM | Yoisungnern et al. (2015)
Balb/c mouse embryos at 2-cell stage | In vitro | K_2_Cr_2_O_7_ and CaCrO_4_ at 0.02–2.0 μg/L (20, 2 and 0.2 μM and 40, 4, and 0.4 μM, respectively) | ↓ blastocyst maturation after 3 d of culture with both salts; K_2_Cr_2_O_7_ arresting all at 4-cell stage at high dose; ↓ hatching, both salts; ↑ implantation CaCrO_4_ | Jacquet and Draye (1982)
Mechanisms affecting bone development
Rat, Sprague-Dawley, male | i.p. injection | 60 μg/kg K_2_Cr_2_O_7_, single dose 48 hr | ↑ TSH, effects on follicle morphology including atrophy; ↓ free T4, T3, follicle size; Pretreatment (i.p.) with ascorbic acid inhibits effects on hormones, treatment with mixture produces nonstatistically significant effects on hormones and morphology | Qureshi and Mahmood (2010)
Immortalized rat osteoblasts (FFC cells) | In vitro | 0.1–100 μM Cr(VI) oxide | ↓ cell viability (measured as ALP activity as a marker of cytotoxicity); Mitigated by vitamin C; not by vitamins B2 and E | Ning and Grant (1999)
Immortalized rat osteoblasts (FFC cells) | In vitro | 0.1, 0.5, 1.0 μM Cr(VI) oxide | ↓ protein synthesis at 0.1 μM, ↓ DNA, RNA synthesis at all doses; No change in collagen synthesis; ↓ production of collagen fibers, mitigated by ascorbic acid; Lower doses suppressed collagenase activity (measured by L-leucine release) more than high doses (up to 100 μM) | Ning et al. (2002)
Immortalized rat osteoblasts (FFC cells) | In vitro | 0.1–100 μM Cr(VI) oxide | ↓ cell viability (measured as ALP activity as a marker of cytotoxicity), partially mitigated by pretreatment to deplete GSH.; No change in GSH content; ↓ glutathione reductase activity after 48 hr at 0.1–1 μM Cr(VI) | Ning and Grant (2000)
Mechanisms affecting insulin regulation
Wistar rats, exposed via drinking water from GDs 9–14; F1 males evaluated on PND 59 | Oral (drinking water) | 50, 100, or 200 mg/L K_2_Cr_2_O_7_, GDs 9–14. Euthanasia on PND 60 | ↓ insulin receptor protein, IRS-1, and p-IRS-1^tyr632^ in liver and gastrocnemius muscle; ↑ Akt^Ser473^ and no change in AKT in liver; ↓ Akt and nonmonotonic effect on Akt^Ser473^ in gastrocnemius muscle; ↑ GLUT 2 in liver; ↓ GLUT 4 in gastrocnemius muscle; ↑ PPARγ expression | Shobana et al. (2017)
Oxidative stress and apoptosis in the placenta
Timed pregnant Sprague-Dawley rats | Oral (drinking water) | 50 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5. Euthanasia on GD 18.5 | ↑ hypertrophy, basal zone thickness, pyknotic nuclei (not quantitated); Hemorrhagic lesions observed w/treatment; ↑ apoptosis (TUNEL) in various regions/cell types (AI%); ↑ Casp-3 in yolk sac and metrial gland (maternal compartment), nondetectable in basal and NS in labyrinth zones (fetal); ↑ AIF, Bax, ATM, p53, NOXA, PUMA, p27 all areas (Casp-3 indep); ↓ Bcl-2, Bcl-XL, XIAP | Banu et al. (2017a) [appears to be the same experiment as Banu et al. (2017b)]
Timed pregnant Sprague-Dawley rats | Oral (drinking water) | 50 mg/L K_2_Cr_2_O_7_, GDs 9.5–14.5. Euthanasia on GD 18.5 | ↓ fetal weight, cytokeratin (TC marker), Cyclin D1 in metrial gland, basal and labyrinth zones; ↓ markers for TGCs in basal and labyrinth zones, glycogen cells in basal zone, syncytial trophoblast in labyrinth zone; ↑ marker for uterine NK cells in labyrinth zone; ↑ LPO, H_2_O_2_; ↓ Gpx, SOD activity in whole extracts; ↓ Prdx3, Txn2 mitochondrial expression all areas samples | Banu et al. (2017b)
Human placental tissues | Ex vivo | 0.02 to 1.2 mg/L Cr detected in placental tissue | Placenta from male birth (results from higher Cr concentrations):; ↑ CytoC, Casp-3, apoptosis inducing factor (AIF), vBAX, and p53, Bcl-2, Bcl-XL; ↓ XIAP (x-linked apoptosis inhibitor); Placenta from female birth (results from higher Cr concentrations):; ↑ CytoC, Casp-3, AIF, BAX, Bcl-2, Bcl-XL; Null p53, XIAP | Banu et al. (2018)
Human trophoblastic cell line BeWo | In vitro | 5, 15, 30 μM K_2_Cr_2_O_7_ for 12 and 24 hr | ↑ GPX1 mRNA with 5 mM Cr(VI) treatment after 12 h, dose-dependent; decreased after 24 hr; ↓ GPX1 and SOD1 expression, 15 and 30 μM, 12 and 24 hr; ↓ Catalase and SOD2; mRNA, 5, 15, and 30 μM, after 12 and 24 hr, dose-dependent; ↓ PRDX3 and TXN2, 5 μM, after 24 hr only; ↓ PRDX3 and TXN2 mRNA, 15 and 30 μM, 12 and 24 h | Banu et al. (2018)
Primary human erythrocytes and mitochondria from placenta tissue | In vitro | 0.05, 0.5, 1, 5 μg/mL K_2_Cr_2_O_7_ | ↑ lipid peroxidation level (TBARS); decreased with coadministration of estrogen metabolite 4-OHE2; ↓ SOD and GST activity; SOD increased with coadministration of estrogen metabolite 4-OHE2; GST increased with coadministration of estrogen metabolite 16α-OHE1; ↓ nitric oxide levels in blood; estrogen metabolites caused further reduction | (2017); Sawicka and Długosz (2017)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

## C.3 SUPPORTING EVIDENCE FOR CARCINOGENIC MODE OF ACTION

### C.3.1 Meta-analysis of Cr(VI) and Cancer of the GI Tract

This section describes the methods for the review and meta-analysis of GI cancer risk reported by occupational studies of workers with inhalation exposure to Cr(VI) (toxicological review, Section 3.2.1). Occupational studies that analyzed cancer risks related to Cr(VI) exposure were identified as part of the overall assessment search strategy process as described in the Cr(VI) Protocol (U.S. EPA, 2019b). This search strategy, which was conditioned on terms for Cr(VI), identified 35 potentially relevant citations. Since these searches only identified references that mentioned chromium or related terms in the title or abstract, an additional search strategy was developed to identify studies of occupational groups with routine exposure to Cr(VI). Our list of occupational groups with potential substantial exposure to Cr(VI) included those in categories I or II identified by the Occupational Safety and Health Administration (OSHA; see Table C-42) (Shaw Environmental, 2006). Group I industries are “primary industry sectors where the majority of occupational exposures occur to hexavalent chromium” while Group II industries “represent industries with limited potential for occupational exposure to hexavalent chromium; consequently, fewer data were available on occupational exposures and controls for these industries.” This search resulted in 2,341 references.

Titles and abstracts for the second set of the references were screened by seven individuals using Distiller imposing a rule that each study be screened by two reviewers; conflicts were resolved by discussion. Screening decisions were guided by a PECO (population, exposure, comparator, outcome) statement designed to capture studies examining associations of cancers of the GI tract with Cr(VI)-exposed occupations (see Table C-42). For our initial screening stage, we included all cancer sites along the digestive tract. Different studies used different naming conventions, partially due to the use of differing International Classification of Disease (ICD) coding versions.

Table C-42 PECO for screening occupational studies relevant to Cr(VI)

PECO element | Evidence
[underlined: P]opulation | Human including epidemiological studies, case-control studies, cohort/prospective studies, follow-up studies, occupational mortality studies
[underlined: E]xposure | Industries including any in group I or group II. Include analyses of cancer in relation to occupation (e.g., stomach cancer and occupation in Sweden).
[underlined: E]xposure | Group I | Group II
[underlined: E]xposure | Chromate or chromium production, ferrochrome production | Chromium dye production
[underlined: E]xposure | Chromated copper arsenate producers | Chromium catalyst users
[underlined: E]xposure | Chromium catalyst production | Chromium dioxide producers
[underlined: E]xposure | Chromium metal production | Chromium sulfate producers
[underlined: E]xposure | Chromium plating, chrome plating, electroplating | Leather work and tanning, tanners
[underlined: E]xposure | Stainless steel production | Portland cement work
[underlined: E]xposure | Welding, Stainless steel (carbon steel welding low prevalence of exposure to generally low levels) | Producers of refractory brick
[underlined: E]xposure | Chromium pigment production | Nonferrous superalloy producers and users
[underlined: E]xposure | Paint and coatings production | Producers of precast concrete products
[underlined: E]xposure | Printing ink producers | Textile dying
[underlined: E]xposure | Plastic colorant producers and users | Producers of colored glass
[underlined: E]xposure | Plating mixture production | Printing – if working with pigments
[underlined: E]xposure | Grinders, polishers (stainless steel) | Aircraft manufacturing; aerospace
[underlined: E]xposure | Wood preserving | Brick masons, bricklayers
[underlined: E]xposure | Painters – if in industry like shipbuilding, automobile manufacture; painting metals | Metal casting, cutting
[underlined: E]xposure | Steel and iron foundry workers
[underlined: E]xposure | Steel mills
[underlined: C]omparator | Analyses of mortality due to cancer or incidence of cancer and associations with occupational groupings (industries; professions)
[underlined: O]utcome | Gastrointestinal tract cancers (incidence, prevalence, mortality)^a^
[underlined: O]utcome | Specific GI cancers identified by ICD-10, -9, -8 or -7 codes, including:
[underlined: O]utcome | Oral cavity [ICD 140–149 (includes cancers of the mouth, lip, tongue, gum, or oropharynx)]
[underlined: O]utcome | Esophagus (ICD 150)
[underlined: O]utcome | Stomach (ICD 151)
[underlined: O]utcome | Small intestine [ICD 152 (includes the duodenum)]
[underlined: O]utcome | Colon (ICD 153)
[underlined: O]utcome | Rectum [ICD 154 (includes the rectosigmoid junction and anus)

a As noted above, nomenclature for cancer sites varied across studies. Some of the alternative designations included: buccal cavity, oral cavity; salivary glands; pharynx; hypopharynx; cardia, corpus, gastric, gastric cardia; bowel, intestine, large intestine; colorectal; digestive tract, digestive system, digestive organs (and peritoneum), gastrointestinal tract.

A total of 199 references were identified during title and abstract screening, and these underwent full-text screening by three reviewers who resolved conflicts via discussion. Of these 199 references, 97 references were retained; the majority (93) were uniquely identified references. A snowball search was conducted by cross-checking the reference lists identified using the two search strategies with the studies included in the three recent meta-analyses, which resulted in identification of an additional 20 references. In total, 35 references from the previous literature searches, 93 references from the subsequent occupationally focused search, and 20 references from the snowball search of the reference lists in the three most recent meta-analyses were included in this review. Of these, 21 studies were not included because they were earlier follow-ups, the cohorts were not exposed to Cr(VI), or they did not contain results for site-specific GI tract cancers.

#### C.3.1.1 Study evaluation criteria

Studies were evaluated with respect to population selection; exposure and outcome evaluation; confounding; analysis; selective reporting; sensitivity; and overall confidence, following the framework outlined in the IRIS Handbook (U.S. EPA, 2022b). Criteria were developed for the exposure domain to identify those studies that used exposure assessment definitions that identified groups with higher certainty and prevalence of exposure to Cr(VI) (U.S. EPA, 2019b). For the evaluation of selected outcomes, we had higher confidence in studies of cancer incidence compared with mortality. Cancer deaths ascertained from death certificates were considered a valid outcome ascertainment method, acknowledging the potential for misdiagnosis of the underlying cause of death and subsequent under ascertainment, particularly for cancers with longer survival periods. We had greater confidence in cancer incidence and mortality coding for stomach cancer compared with other sites in the gastrointestinal tract because the probability that the diagnosis on the death certificate is the same as that in the hospital medical records is higher (Percy et al., 1981; Percy et al., 1990).

With a few exceptions, most of the studies compared cancer incidence or mortality in an occupational group to that in the country or other geographical region in which the facilities were located, by calculating a standardized incidence ratio (SIR) or standardized mortality ratio (SMR). This study design can be subject to the healthy worker effect, a type of selection bias that results in an underestimate of the relative risk because individuals in the workforce are a healthier population than a general population that might be used for comparison. This limitation, and reduction in study sensitivity, is not generally present in studies using internal comparisons. Greater confidence was given to studies that considered major confounders of the association between Cr(VI) exposure and GI tract cancers. Risk factors for these cancers vary by site, but generally include sex, age, race/ethnicity, and geographic region. Individual-level information on other risk factors, such as smoking and alcohol consumption that could be risk factors for certain GI tract cancers and that might differ between the occupational groups and comparison populations, was not usually available to adjust the SMRs or SIRs, but the magnitude of bias likely differed across the occupational categories. Other risk factors such as obesity, H. pylori infection, dietary factors and family history of such cancers, likely were not differentially associated with chromium-exposed occupations or jobs and thus any differences would be expected to be random. Appropriate analysis methods were prioritized and largely included standardized ratios for mortality or incidence of cancer or relative risk estimates for comparisons of exposure groups within the study population; in a few studies, odds ratios were estimated for case-control study designs.

#### C.3.1.2 Evaluation of exposure to Cr(VI)

For the purposes of this meta-analysis, only occupational studies were considered, and studies were evaluated with respect to certainty of exposure to hexavalent chromium. Occupational groups were identified after inventorying the database of references, and specific criteria developed for “good,” “adequate,” and “deficient” ratings for decreasing certainty of exposure within each one. Many of the identified studies were registry based, with occupation inferred based on a standardized set of occupation or industry codes. In the absence of further information on potential for Cr(VI) exposure, the certainty of exposure for these studies was deemed “deficient.”

Since the focus of this meta-analysis was occupational exposure to Cr(VI), criteria to evaluate the certainty of exposure to Cr(VI) were developed specific to occupational groups. Exposure certainty was rated as “good,” “adequate,” or “deficient” using the guidelines in Table C-43. Potential bias in exposure assignments, and other domains of risk of bias and sensitivity, were evaluated using the methods described in the IRIS Handbook (U.S. EPA, 2022b). The results of the study evaluations with domain-specific ratings and overall confidence (“high,” “medium,” or “low”) are available in HAWC for the cancer mortality studies with comparisons to external populations (https://hawcprd.epa.gov/summary/visual/assessment/499/Occup-Studies-GI-Cancer-External-comp/) and studies with comparisons within the target study population (https://hawcprd.epa.gov/summary/visual/assessment/499/Occupational-Studies-Gastrointestinal-Cancer/) and are shown in Table C-44.

Table C-43 Occupational group-specific criteria for rating certainty of exposure to Cr(VI)

Occupation group | Potential coexposures | Good | Adequate | Deficient
Brick masons/stone masons/tile setters/brick layers/cement or concrete workers; The main source of Cr(VI) exposure in this group comes from exposure to Portland cement (production or use). | Asbestos, cement dust, silica, fiberglass, talc, solvents, asphalt; (US DHHS, 1990; Seta et al., 1988; Pedersen and Sieber, 1988) | Portland cement production, exposure assigned using task-related data from job histories and other industrial hygiene evidence | Cement production, exposure assigned using task-related data from job histories | Cohort studies of bricklayers or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Chromate production, ferrochromium industry; The main source of Cr(VI) exposure in this group comes from exposure to chromate and related compounds (production or use). | Asbestos, nickel, acid and alkali mists, nitrogen oxides, cyanide, solvents; (IARC, 1990) | Cohort studies of chromate workers, including chromate production, ferrochromium industry, with categories based on tasks involving direct exposure to Cr(VI) | Cohort studies of chromate workers, including chromate production, ferrochromium industry, or case-control studies, with categories based on (1) ever employment or duration of employment, or (2) standard codes for industry/occupation. | Cohort studies of chromate workers, including chromate production, ferrochromium industry, or case-control studies, where the exposure assessment description was not sufficient to determine the prevalence or frequency of exposure to Cr(VI).
Building construction/carpenters/wood workers; The main source of Cr(VI) exposure in this group comes from exposure to refractory brick or Portland cement (construction, building) and from wood treated with chromated copper arsenate (CCA). | Asbestos, silica, wood dust, formaldehyde, wood preservatives, solvents; (Robinson et al., 1996) | Cohort studies of construction workers, carpenters, or woodworkers with categories based on tasks in Portland cement mixing or wood preservation or working with treated wood | Cohort studies of construction workers, carpenters or woodworkers with categories based on tasks in cement mixing (nonspecific) or broader woodworking categories. | Cohort studies of construction workers, carpenters or woodworkers, or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Automotive workers; The main source of Cr(VI) exposure in this group comes from exposure to metalwork (e.g., welding) and to automotive paint. | Solvents, welding fumes, asbestos in brakes and clutches, metal welding fluids; (Gibel et al., 1985) (OSHA, 2006a) | Cohort studies with task-specific exposure assignments based on job histories, specifically spray painting, welding, or metal cutting (see criteria for painting, welding or metal work) with supplemental industrial hygiene evidence | Cohort studies with task-specific exposure assignments based on job histories, specifically spray painting, welding, or metal cutting (see criteria for painting, welding or metal work, but with no supplemental information | Cohort studies of automotive workers, or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Aircraft manufacturing workers; The main source of Cr(VI) exposure in this group comes from exposure to metalwork (e.g., welding) and to aircraft paint. | Solvents, heavy metal salts, welding fumes, epoxy resins, asbestos, other fibers, ionizing radiation; (Lipworth et al., 2011; Costa et al., 1989) | Cohort studies with task-specific exposure assignments based on job histories, specifically spray painting, welding, or metal cutting (see criteria for painting, welding or metal work), with supplemental industrial hygiene evidence; sprayers and hosemen | Cohort studies with task-specific exposure assignments based on job histories, specifically spray painting, welding, or metal cutting (see criteria for painting, welding or metal work, but with no supplemental information | Cohort studies of aircraft manufacturing workers or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Painter/paint product/paint, and coating manufacturers The main source of Cr(VI) exposure in this group comes from exposure to plaster and chromium-based pigments (usually used in marine, automotive, aircraft, etc. paints). | Solvents, pigments, aromatic azo dyes, PAHs, resins; (IARC, 2010) | Cohort studies with task-specific exposure assignments based on job histories; spray painting or coating in the marine, automotive or aircraft manufacturing industries, with supplemental industrial hygiene evidence | Cohort studies with task-specific exposure assignments based on job histories; spray painting or coating in the marine, automotive or aircraft manufacturing industries, but with no supplemental information | Cohort studies of painters, plasterers, or paint manufacturing workers, or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Printers; The main source of Cr(VI) exposure in this group comes from exposure to chromium-based pigments in ink. | Solvents, dyes, lead salts; (Lynge et al., 1995) | Cohort studies with task-specific exposure assignments based on job histories; photoengravers, press operators, with supplemental industrial hygiene evidence | Cohort studies with task-specific exposure assignments based on job histories; photoengravers, press operators, but with no supplemental information | Cohort studies of printing workers or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Textiles; The main source of Cr(VI) exposure in this group comes from exposure to chromium-based pigments in fabric dyes. | Solvents, textile dusts and fibers, formaldehyde, dyes; (IARC, 1998) | Cohort studies with task-specific exposure assignments based on job histories (e.g., textile dying), with supplemental industrial hygiene evidence | Cohort studies with task-specific exposure assignments based on job histories (e.g., textile dying), but with no supplemental information | Cohort studies of textile workers or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Welder/metal fumes; The main source of Cr(VI) exposure in this group comes from welding on stainless steel, and intensity of exposure varies by specific welding technique. For welding, highest exposure during shielded metal arc welding, less for gas metal arc welding and tungsten inert gas welding (Pesch et al., 2018). | Nickel and other metals, arsenic asbestos, formaldehyde, silica dust; (IARC, 1990) (IARC, 2018) | Cohort studies with task-specific exposure assignments based on job histories; stainless steel welding: shielded metal arc welding, or stainless steel welding: unspecified technique but with monitoring data or other Cr(VI)-specific information | Cohort studies with task-specific exposure assignments based on job histories; stainless steel welding (unspecified technique) | Cohort studies with task-specific exposure assignments based on job histories; gas metal arc welding, tungsten inert gas welding; or cohort studies of welders or case-control studies, where occupation was assigned on the basis of standard codes for industry/occupation
Tanners; The main source of Cr(VI) exposure in this group comes from the “two bath” tanning process which uses hexavalent chromium salts as the tanning material (Stern, 2003). | Benzidine-based azo dyes, aromatic organic solvents, formaldehyde, airborne leather dust; (IARC, 1981) | Work processes involving leather tanning and cohort description supports that at least 50% of cohort first employed as leather tanners when two-bath process was still used (pre 1940s in United States) and before mechanization was introduced. | Work processes involving leather tanning and cohort description supports that a large portion of cohort first employed as leather tanners when two-bath process was still used (pre 1940s in United States) and before mechanization was introduced | Work processes involving leather tanning and cohort description supports that most of the cohort (>70%) first employed as leather tanners when one bath process was used (post 1940s in United States); or occupation was assigned based on standard codes for industry/occupation
Metal Workers; The main source of Cr(VI) exposure in this group comes from work with chrome plating, stainless steel and steel alloys (tasks include: plating, melting, pouring, cutting, grinding and welding operations). | Nickel (electroplating), polynuclear aromatic hydrocarbons, silica, carbon monoxide, nickel, phenol, formaldehyde, isocyanates, amines; (IARC, 1990) | Cohort studies analyzing stainless steel categories/tasks with some monitoring data or industrial hygiene documentation. Stainless steel machining, production of stainless steel products (grinding, polishing) (based on job histories), stainless steel production (based on job histories), steel foundries (by work area/task) | Cohort studies involving steel foundries with subgroup analyses. Cohort studies analyzing stainless steel categories with no or minimal monitoring data. | Iron or steel foundries; If occupation was assigned on the basis of standard codes for industry/occupation

The meta-analyses focused on the studies considered to be “medium” or “high” overall confidence for which EPA had greater certainty in the exposure assessment for Cr(VI) and minimal concern for other sources of bias. These studies reported a variety of effect estimates, including standardized incidence or mortality ratios, standardized risk ratios, odds ratios, and proportionate mortality ratios. Studies that calculated proportionate mortality ratios were not included. In some instances, multiple risk estimates were reported—for example, for men or women separately, for exposure or occupational subgroups, or by latency period. A priori, we selected risk estimates (1) that were adjusted for potential confounders including age, sex, time period, and geographic region; (2) for the longest latency period; (3) from the most recent follow-up of a specific study cohort; and (4) for the most highly exposed subgroup of the study population. A comparison of the studies included in the three most recent meta-analyses and this analysis, with our rationale for decisions to exclude, are in Table C-44. The table indicates the citations included in our metaanalysis and those in the three most recent meta-analyses. The studies included in each metaanalysis comprised an overlapping but different set of studies reflecting the various time periods used for the literature searches, the inclusion criteria, and the results of the evaluations of study “quality” used in the studies. In this analysis, the primary reason for considering a study “low” confidence was that exposure to Cr(VI) in the population was too uncertain.

When reviewing the studies captured by our literature search and evaluation of studies, some cancer sites or groupings were difficult to reconcile across studies due to differences in ICD codes included, for example, or changes in coding practices and diagnostic naming conventions over time and across geographical sites. Consequently, determining whether common cancer sites were contained within some of the groupings was difficult. Further, in some cases, the number of studies for a given cancer site was small enough (and heterogenous enough) that a meta-analysis seemed unlikely to yield useful information. Consequently, we performed quantitative metaanalysis to derive summary risk estimates for a subset of GI tract cancers by site: esophagus, stomach, rectum, and colon. For each of these four sites, more studies were available to include in a summary effect estimate, and these studies used relatively consistent definitions for these specific cancer sites.

Separate meta-analyses were performed to obtain summary estimates from studies reporting odds ratios (stomach cancer, esophageal cancer), and from studies reporting SMR, SIR, or SRR estimates (all four sites). All analyses were performed using the “metafor” package in R, with a random effects model. This package was also used to generate forest plots. The potential for publication bias was evaluated using the Egger’s test (Egger et al., 1997) for funnel plot asymmetry. The I2 statistic value is used to represent the percentage of variation across studies that is due to heterogeneity rather than chance.

Table C-44 Comparison of studies included in meta-analyses or that met PECO, with search phase, study evaluation rating, and rationale for exclusion in EPA meta-analysis

All included | EPA included | Welling included | Deng included | Suh included | Search | Overall rating | Rationale for exclusion
Andersson et al. (2010) | x | | | | PECO_1 | Medium
Birk et al. (2006) | x | | x | x | PECO_1 | Medium
Davies et al. (1991) | x | x | | x | PECO_1 | Medium
Franchini et al. (1983) | x | x | | x | PECO_1 | Medium
Gibb et al. (2015) | x | | x | | PECO_1 | Medium
Hayes et al. (1989) | x | x | x | x | PECO_1 | Medium
Huvinen and Pukkala (2013) | x | | x | | PECO_1 | Medium
Huvinen and Pukkala (2016) | x | x | | | PECO_1 | Medium
Koh et al. (2013) | x | x | | | PECO_1 | Medium
Korallus et al. (1993) | x | x | x | x | PECO_1 | Medium
Langard et al. (1990) | x | x | | x | PECO_1 | Medium
Rafnsson et al. (1997) | x | | | | PECO_1 | Medium
Rosenman and Stanbury (1996) | x | x | | | PECO_1 | Medium
Silverstein et al. (1981) | x | x | | x | PECO_1 | Medium
Sorahan and Harrington (2000) | x | x | | x | PECO_1 | Medium
Sorahan et al. (1987) | x | x | x | | PECO_1 | Medium
Hayes et al. (1979) | x | | | | PECO_1 | Medium
Kano et al. (1993) | x | x | | x | PECO_1 | Medium
Becker (1999) | x | x | | x | PECO_2 | Medium
Boice et al. (1999) | x | | x | x | PECO_2 | Medium
Dalager et al. (1980) | x | | | x | PECO_2 | Medium
Danielsen et al. (1996) | x | | | | PECO_2 | Medium
Delzell et al. (2003) | x | | | | PECO_2 | Medium
Edling et al. (1986) | x | x | | | PECO_2 | Medium
Garabrant and Wegman (1984) | x | x | | | PECO_2 | Medium
Garabrant et al. (1988) | x | | | | PECO_2 | Medium
Hansen et al. (1996) | x | | | | PECO_2 | Medium
Iaia et al. (2006) | x | | x | x | PECO_2 | Medium
Jakobsson et al. (1993) | x | x | x | | PECO_2 | Medium
Jakobsson et al. (1997) | x | x | x | | PECO_2 | Medium
Kaerlev et al. (2000) | x | | | | PECO_2 | Medium
Kusiak et al. (1993) | x | | | | PECO_2 | Medium
Lipworth et al. (2011) | x | x | x | | PECO_2 | Medium
Lynge et al. (1995) | x | | | | PECO_2 | Medium
Mikoczy and Hagmar (2005) | x | x | | | PECO_2 | Medium
Montanaro et al. (1997) | x | x | x | x | PECO_2 | Medium
Morgan et al. (1981) | x | | | | PECO_2 | Medium
Moulin et al. (1990) | x | x | x | x | PECO_2 | Medium
Moulin et al. (1993a) | x | x | x | x | PECO_2 | Medium
Park et al. (2005) | x | | x | | PECO_2 | Medium
Polednak (1981) | x | | | | PECO_2 | Medium
Ramanakumar et al. (2008) | x | | | | PECO_2 | Medium
Santibanez et al. (2008) | x | | | | PECO_2 | Medium
Sciannameo et al. (2019) | x | | | | PECO_2 | Medium
Sjögren et al. (1987) | x | | | | PECO_2 | Medium
Sorahan et al. (1994) | x | | x | x | PECO_2 | Medium
Tarvainen et al. (2008) | x | | | | PECO_2 | Medium
Veyalkin and Gerein (2006) | x | | | | PECO_2 | Medium
Xu et al. (1996b) | x | x | | | PECO_2 | Medium
Olsen et al. (1988) | x | | | | PECO_2 | Medium
Simonato et al. (1991) | x | x | x | x | PECO_2 | Medium
Axelsson et al. (1980) | x | x | | | Snowball ID | Medium
Costantini et al. (1989) | x | x | | x | Snowball ID | Medium
Dab et al. (2011) | x | | x | | Snowball ID | Medium
Hara et al. (2010) | x | x | | x | Snowball ID | Medium
Horiguchi et al. (1990) | x | x | x | x | Snowball ID | Medium
Pippard et al. (1985) | x | x | x | x | Snowball ID | Medium
Smailyte et al. (2004) | x | x | x | | Snowball ID | Medium
Deschamps et al. (1995) | x | x | | x | Snowball ID | Medium
Aragones et al. (2002) | | | | | PECO_1 | Low | Low confidence due to exposure assessment, which was based on self-reported occupation at one timepoint. Concern that occupation at one point in time does not represent etiologically relevant time window.
Guberan et al. (1989) | | | x | x | PECO_1 | Low | Low confidence related to nonspecific exposure definition.
Koh et al. (2011) | | | x | | PECO_1 | Low | Main limitation is uncertain potential for exposure (highest likelihood for production and maintenance, but duration unknown and use of last held job could introduce misclassification) and low numbers of cases.
Parent et al. (1998) | | x | | | PECO_1 | Low | Low confidence due to the nonspecific nature of the exposure assignments.
Satoh et al. (1981) | | x | | x | PECO_1 | Low | Although potential for chromium exposure seems clear, there is little information to inform potential for selection bias or outcome ascertainment, and low number of cases (n = 11).
Sweeney et al. (1985) | | x | | | PECO_1 | Low | Main limitations are uncertain potential for chromium exposure and low number of deaths for certain cancer sites.
Walrath et al. (1987) | | x | | | PECO_1 | Low | Main limitation is unclear potential for chromium exposure.
Andjelkovich et al. (1992) | | | | | PECO_2 | Low | Low confidence study due to lack of information on likelihood of Cr(VI) exposure.
Andersen et al. (1999) | | | | | PECO_2 | Low | Low confidence study due to lack of information on potential for Cr(VI) exposure, lack of consideration of latency.
Bertazzi and Zocchetti (1980) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding potential for chromium exposure.
Bethwaite et al. (1990) | | | | | PECO_2 | Low | Low confidence study due to lack of certainty regarding Cr exposure.
Bouchardy et al. (2002) | | | | | PECO_2 | Low | Main limitation is lack of certainty for occupation in general and for chromium exposure potential.
Brown et al. (2002) | | | | | PECO_2 | Low | Main limitation is the lack of certainty regarding chromium exposure and potential healthy worker effect.
Brownson et al. (1989) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding exposure (and occupation only at time of diagnosis).
Bulbulyan et al. (1999) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding chromium exposure.
Chiazze et al. (1980) | | | | | PECO_2 | Low | Main limitations are lack of certainty regarding chromium exposure, and uncertainty due to missing data. Further limitations are small sample size and use of PMR analysis.
Chow et al. (1994) | | | | | PECO_2 | Low | Main limitation is the lack of certainty regarding chromium exposure and potential healthy worker effect.
Chow et al. (1995) | | | | | PECO_2 | Low | Main limitation is the lack of certainty regarding chromium exposure and potential healthy worker effect.
Cocco et al. (1998) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding chromium exposure.
Costa et al. (1989) | | | | | PECO_2 | Low | Main limitation is lack of specificity about which workers might be exposed to chromium and inclusion of short-term workers, lack of information on longest held or usual occupational group.
Danielsen et al. (1993) | | | | | PECO_2 | Low | Low confidence study, given short time period (1977 onward) that stainless steel was in use during the overall study period from 1940–1979.
Divine and Barron (1986) | | | | | PECO_2 | Low | Low confidence primarily due to uncertainties in exposure domain. Type of welding metal was not reported so there is low certainty about the extent of exposure to chromium in the industry.
Dubrow and Wegman (1984) | | | | | PECO_2 | Low | Low confidence due to uncertainties in the exposure domain due to likely misclassification in exposure assignments; usual occupation on death certificate and broad exposure categories.
Dubrow and Gute (1988) | | | | | PECO_2 | Low | Primary limitation is the nonspecific nature of the exposure assignments and low sensitivity.
Engel et al. (2002) | | | | | PECO_2 | Low | Although the greater specificity in the incident cancer ascertainment is a strength, the nonspecific nature of the exposure assignments based on occupational and industry codes constrained any conclusions regarding any associations with Cr(VI).
Finkelstein and Verma (2005) | | | | | PECO_2 | Low | Exposure based on membership in the bricklayers union is nonspecific with large uncertainties in the prevalence, frequency and intensity of exposure to Cr(VI).
Golka et al. (2012) | | | | | PECO_2 | Low | In addition to the nonspecific occupational and exposure group definitions for Cr(VI), the numbers of cases in the chromium VI-relevant groups were small.
Greene et al. (1979) | | | | | PECO_2 | Low | The lack of specificity in the exposure assignments is the major limitation, and the number of deaths was small.
Huebner et al. (1992) | | | | | PECO_2 | Low | Although design and analysis are appropriate, main limitation is uncertain potential for chromium exposure.
Jansson et al. (2015) | | | | | PECO_2 | Low | Low confidence study due to lack of information on potential for Cr(VI) exposure and lack of consideration of latency.
Ji and Hemminki (2006) | | | | | PECO_2 | Low | Low confidence study due to lack of information on potential for Cr(VI) exposure.
Kaerlev et al. (2002) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Kang et al. (1997) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Keller and Howe (1993) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Kraus et al. (1982) | | | | | PECO_2 | Low | Certainty regarding chromium exposure is low and it is unclear how census data were used to calculate expected number of deaths.
Lindsay et al. (1993) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding chromium exposure.
Macleod et al. (2017) | | | | | PECO_2 | Low | Low confidence study due to lack of certainty regarding chromium exposure.
Malker and Gemne (1987) | | | | | PECO_2 | Low | Main limitation is lack of certainty regarding chromium exposure.
Matanoski et al. (1986) | | | | | PECO_2 | Low | Main limitation is lack of information on potential for chromium study.
Mcmillan and Pethybridge (1983) | | | | | PECO_2 | Low | Low numbers of deaths, uncertain potential for chromium exposure, and questionable statistical analysis.
Melkild et al. (1989) | | | | | PECO_2 | Low | Main limitation is small sample size and uncertainty regarding chromium exposure.
Minder and Beerporizek (1992) | | x | | | PECO_2 | Low | Main limitation is lack of certainty for chromium exposure potential.
Park et al. (1994) | | | | | PECO_2 | Low | Low confidence due to the nonspecific nature of the exposure assignments.
Pukkala et al. (2009) | | x | | | PECO_2 | Low | Low confidence study due to lack of information on potential for Cr(VI) exposure, lack of consideration of latency.
Richiardi et al. (2012) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Robinson et al. (1995) | | x | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Salg and Alterman (2005) | | x | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Silverstein et al. (1985) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure. The welding conducted at the plant was not likely to have involved exposure to Cr(VI).
Sjödahl et al. (2007) | | x | | | PECO_2 | Low | The large size of the cohort, almost complete ascertainment, number of cancer cases, and analysis of cancer incidence is a strength, allowing for analyses of relatively rare cancer types. The nonspecific nature of the exposure definition, however, reduced certainty that prevalence of Cr(VI) exposure was adequate.
Stellman and Garfinkel (1984) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Stern (2003) | | | x | | PECO_2 | Low | Main limitation is low potential for chromium exposure during study period.
Sun et al. (2002) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Urbaneja Arrúe et al. (1995) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Wang et al. (1999) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Westberg et al. (2013) | | | | | PECO_2 | Low | Main limitation is unclear potential for chromium exposure.
Yuan et al. (2011) | | | | | PECO_2 | Low | Main limitation is lack of information on case and control selection and use of a single biomarker measurement of total chromium of unclear timing after diagnosis.
Ahn et al. (2006) | | x | | | Snowball ID | Low | There is some likelihood of Cr(VI) exposure in certain process areas, but industrial hygiene measures indicate levels could be fairly low. Combined with rather short follow-up and low numbers of cases, it may be difficult to infer cancer associations with Cr(VI).
Amandus (1986) | | x | | | Snowball ID | Low | Main limitation is uncertainty regarding likelihood of Cr(VI) exposure.
Blair (1980) | | | | x | Snowball ID | Low | Low confidence study due to lack of certainty regarding Cr exposure.
González et al. (1991) | | x | | | Snowball ID | Low | Exposure definitions were not specific to Cr(VI).
Järvholm et al. (1982) | | x | | | Snowball ID | Low | Main limitations are small sample and unclear potential for chromium exposure.
Kneller et al. (1990) | | x | | | Snowball ID | Low | Main limitation is lack of uncertainty for chromium exposure potential.
Krstev et al. (2005) | | x | | | Snowball ID | Low | Main limitation is lack of certainty regarding potential for chromium exposure.
Mallin et al. (1989) | | x | | | Snowball ID | Low | Main limitation is uncertain potential for chromium exposure.
Mcdowall (1984) | | x | | | Snowball ID | Low | Main limitation is lack of information on potential for chromium exposure. Classification by tasks within this cohort of cement workers allowed adequate exposure contrast for dust exposure, but whether the exposures were to Portland cement is unclear. Therefore, there is less certainty about exposure to Cr(VI).
Santibañez et al. (2012) | | x | | | Snowball ID | Low | Main limitation is unclear potential for chromium exposure.
Stern et al. (2001) | | x | | | Snowball ID | Low | Main limitation is unclear potential for chromium exposure.
Becker et al. (1991) | | | x | | PECO_1 | Exclude | Earlier study of the cohort reported by Becker (1999).
Gibb et al. (2000b) | | | | x | PECO_1 | Exclude | Earlier study of the cohort reported by Gibb et al. (2015).
Luippold et al. (2003) | | | x | x | PECO_1 | Exclude | No GI tract cancer results.
Park et al. (2004) | | | x | | PECO_1 | Exclude | Lung cancer only.
Proctor et al. (2016) | | | x | | PECO_1 | Exclude | Lung cancer only.
Rafnsson and Jóhannesdóttir (1986) | | | | | PECO_1 | Exclude | Earlier study of the cohort reported by Rafnsson et al. (1997).
Sorahan et al. (1998) | | | x | | PECO_1 | Exclude | No analyses for GI tract cancer.
Steenland et al. (1991) | | | x | | PECO_1 | Exclude | Cohort was not exposed to Cr(VI).
Steenland (2002) | | | x | | PECO_1 | Exclude | Cohort was not exposed to Cr(VI).
Takahashi and Okubo (1990) | | | x | | PECO_1 | Exclude | Earlier study of the cohort reported by Hara et al. (2010).
Moulin (1995) | | x | | | PECO_2 | Exclude | Letter to the editor focused on lung cancer.
Becker et al. (1985) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Becker (1999).
Delzell et al. (1993) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Delzell et al. (2003).
Iaia et al. (2002) | | | | | PECO_2 | Exclude | In Italian. Same analyses as Iaia et al. (2006).
Mastrangelo et al. (2002) | | | | | PECO_2 | Exclude | Meta-analysis.
Mikoczy et al. (1994) | | | x | | PECO_2 | Exclude | Earlier study of the cohort reported by Mikoczy and Hagmar (2005).
Moulin et al. (2000) | | | x | | PECO_2 | Exclude | Focus of the study is on lung cancer.
Sorahan and Cooke (1989) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Sorahan et al. (1994).
Stern et al. (1987) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Stern (2003).
Svensson et al. (1989) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Jakobsson et al. (1997).
Veyalkin and Milyutin (2003) | | | | | PECO_2 | Exclude | Earlier study of the cohort reported by Veyalkin and Gerein (2006).

#### C.3.1.3 Results

As shown in Table 3-13 in the toxicological review, the summary effect estimates showed small increases in risk for each cancer site associated with Cr(VI) exposure, although only the estimate for rectal cancer was statistically significant. Few studies reported odds ratios, but in each case (esophagus and stomach), summary effect estimates based on these studies were somewhat higher compared with summary estimates based on other relative risk measures (although neither odds ratio-based estimate was statistically significant). No evidence of funnel plot asymmetry was found based on Egger's regression test, indicating that publication bias was not likely to be present.

Summary effect estimates were also derived for each cancer site, stratified by occupational grouping (see Table C-45 and Figures C-15 to C-20). This separation by occupational grouping did show some expected patterns for colon cancer risk estimates (see Figure C-19) in that the occupations with a higher certainty of exposure to Cr(VI) (i.e., ferrochromium, chromate production, stainless-steel workers, chromium pigment-exposed workers) showed higher summary effect estimates. Inconsistencies remained among the studies overall, however, and the results for cancer of the rectum did not show a similar pattern of risk (see Figure C-20).

All risks were either slightly above or close to the null (RRs ranging from 1.01 to 1.45) with the exception of stomach cancer among tannery workers [relative risk (RR) of 0.72]. For example, when looking at stomach cancer, there was a (nonsignificant) decreased risk for tannery workers, and a (nonsignificant) increased risk for those working with metal coatings and metal platers (RRs of 0.72 and 1.26, respectively). Risks for other occupational groups were close to the null, ranging from 1.01 to 1.10. Similarly, variation within occupational groups occurred—the group “ferrochromium, chromate production, stainless-steel workers,” had modestly elevated risks for esophageal and colon cancer (RRs of 1.22 and 1.26), while risks were very close to 1 for stomach or rectal cancer (RRs of 1.01 and 1.04). Looking across cancer sites, for the occupational groups with four or more estimates, those with a higher certainty of exposure prevalence (i.e., ferrochromium, chromate production and stainless-steel workers, and chromium pigment exposed workers) had higher relative risk estimates for esophageal and colon cancers but not stomach or rectal cancers. The number of studies within another category with more certainty in the probability of Cr(VI) exposure, “estimated or measured chromium exposure,” was too small to calculate a summary estimate. For esophageal cancer, the two studies in this category indicated elevated, but not significant, effect estimates. For colon cancer, this category included two analyses within one study of chromate production workers with exposure prior to and after work process changes that reduced Cr(VI) concentrations. Effect estimates are not consistent with what would be expected, however, since higher risk was observed for the post-change workers. A small number of colon cancer cases contributed to the effect estimates (pre-change n = 7, post-change n = 4), and there was evidence of bias from the healthy worker effect with consequent impacts on sensitivity. Heterogeneity in effect estimates (magnitude and direction) also was evident within occupational groups for a specific cancer site, as shown in the forest plots (see Figures C-15 to C-20).

Table C-45 Summary effect estimates from random effects meta-analysis, by cancer site and occupational group, where four or more estimates are included

Cancer site | Occupational group | Number of individual effect estimates | Summary effect estimate (95% confidence interval) | I^2^
Esophagus | Ferrochromium, chromate production, stainless-steel workers^a^ | 6 | 1.22 (0.90, 1.64) | 0
Esophagus | Chromium pigment-exposed workers | 5 | 1.42 (0.87, 2.32) | 10.6
Stomach | Ferrochromium, chromate production, stainless steel workers | 13 | 1.01 (0.75, 1.35) | 49.9
Stomach | Welders | 5 | 1.10 (0.76, 1.60) | 19.7
Stomach | Tannery workers | 6 | 0.79 (0.56, 1.12) | 12.7
Stomach | Portland cement workers, masons | 4 | 1.02 (0.65, 1.61) | 59.0
Stomach | Chromium pigment-exposed workers | 6 | 1.07 (0.80, 1.42) | 0
Stomach | Metal coatings, metal platers | 6 | 1.26 (0.81, 1.98) | 54.8
Colon | Ferrochromium, chromate production, stainless steel workers | 4 | 1.26 (0.82, 1.91) | 44.0
Colon | Portland cement workers, masons | 4 | 0.88 (0.61, 1.27) | 0
Colon | Chromium pigment-exposed workers | 4 | 1.45 (0.68, 3.09) | 41.7
Rectum | Ferrochromium, chromate production, stainless steel workers^a^ | 10 | 1.04 (0.78, 1.38) | 0
Rectum | Welders | 5 | 1.28 (0.69, 2.41) | 39.2
Rectum | Tannery workers | 4 | 1.32 (0.80, 2.21) | 25.3
Rectum | Chromium pigment-exposed workers | 4 | 1.11 (0.63, 1.98) | 16.7

a Warning displayed during estimation of the summary estimate indicates that “Ratio of largest to smallest sampling variance extremely large. May not be able to obtain stable results.”

These results could be due to misclassification and heterogeneity of Cr(VI) exposure among and within the included studies. Although this analysis included studies that analyzed associations among occupational groups or subgroups with greater certainty of exposure to Cr(VI), variation in the prevalence, frequency, and magnitude of exposure is likely within the exposure groups, which could decrease the ability to detect an association if it existed. Other factors that could contribute to the observed heterogeneity of risk estimates include presence of coexposures and bias due to the use of occupational cohorts. Cancer risk in these industries is likely affected by prevalent exposures to other carcinogens in addition to Cr(VI), which would vary both within and across occupational groupings. As noted in Appendix Table C-43, industries with higher certainty of Cr(VI) prevalence (ferrochromium, chromate production, and stainless-steel workers, and chromium pigment-exposed workers), had occupational settings characterized by different coexposures, which argues against a strong common confounder. In some cases, authors did attempt to adjust for coexposures or restrict the study population to minimize their effect. Most of the studies estimated relative risk using SMRs, which also are subject to a bias toward the null due to the healthy worker effect. The summary effect estimates for esophageal and stomach cancers calculated using odds ratios from the few case-control studies were not subject to this bias and indicated a higher risk. These odds ratio estimates are based on very few studies, however, and are highly uncertain.

Previous meta-analyses reported summary effect estimates for stomach cancer that ranged between 0.93 (Deng et al., 2019) to 1.27 (Welling et al., 2015). A statistically significant increase in risk of stomach cancer was reported from two of the previous five estimates (Welling et al., 2015; Cole and Rodu, 2005). This assessment’s finding of no increased risk (summary RR of 1.01) is within the range of these previous estimates. Two of the five previous meta-analyses included estimates for cancers of the esophagus, colon, and rectum (Gatto et al., 2010; Deng et al., 2019). This assessment’s summary estimate of 1.08 for esophageal cancer was not significantly elevated, and was slightly less than that from Gatto et al. (2010). The effect estimate for colon cancer of 1.10 (95% CI: 0.97, 1.25), was close to the estimate reported by Deng et al. (2019). Finally, this assessment’s estimate of rectal cancer risk was significantly elevated, and very similar to those previously reported (1.18, 95% CI: 1.01, 1.37), compared with 1.17 (Gatto et al., 2010) and 1.14 (Deng et al., 2019).

Figure C-15 Forest plot displaying summary measures for esophageal cancer risk from studies reporting odds ratios.

Figure C-16 Forest plot displaying summary measures for esophageal cancer risk from studies reporting standardized mortality or incidence ratios.

Figure C-17 Forest plot displaying summary measures for stomach cancer risk from studies reporting odds ratios.

Figure C-18 Forest plot displaying summary measures for stomach cancer risk from studies reporting standardized mortality or incidence ratios.

Figure C-19 Forest plot displaying summary measures for colon cancer from studies reporting standardized mortality or incidence ratios.

Figure C-20 Forest plot displaying summary measures for rectal cancer risk from studies reporting standardized mortality or incidence ratios.

### C.3.2 Mechanistic Evidence Organized by the 10 Key Characteristics of Carcinogens

The hazard identification of cancers of the lung and GI tract includes an analysis of whether a mutagenic mode of action (MOA) could be involved in Cr(VI)-induced carcinogenesis. Because a large and diverse set of mechanistic studies was identified that has potential relevance for informing Cr(VI)-induced carcinogenicity in the GI tract and lung, several prioritization factors have been considered to identify the most informative evidence for the MOA analysis for cancer of the GI tract and lung following Cr(VI) exposures.

The first phase of the identification and screening of literature pertinent to the MOA analysis is described in Appendix B.1. Mechanistically relevant studies are not included in the initial PECO criteria, which are intended to identify studies in humans and animals reporting apical health effects data that will be evaluated for reporting quality, risk of bias, and sensitivity. Instead, studies reporting mechanistic data are initially screened and categorized to provide a clearer view of the proposed biological pathways and processes involved in the toxicity of the chemical and to identify critical research gaps. The initial broad literature search for Cr(VI) identified 1,522 Cr(VI) mechanistic studies, which were screened for relevance and sorted into groups primarily based on the 10 key characteristics (KCs) of carcinogens (Smith et al., 2016). These studies, summarized in Appendix Sections C.3.3–C.3.12, were generally prioritized if they measured mechanistically relevant biomarkers in humans exposed to Cr(VI) or were experimental studies conducted in mammals exposed to Cr(VI) or in human primary cells or cell lines.

Because of the importance of determining whether Cr(VI) is mutagenic, it was determined that the evidence that could be most informative for the mutagenic potential of Cr(VI) would be subject to study evaluation for reporting, risk of bias, and sensitivity. This includes test systems in animals that measure mutations (e.g., transgenic rodent assays) and structural and numerical chromosomal aberrations (e.g., the micronucleus assay). The studies identified as most informative for mutagenic risk and evaluated in HAWC are summarized separately below for the GI tract and the lung. All other evidence for genotoxicity and other characteristics of carcinogens are summarized and synthesized as supporting evidence for biological pathways and processes related to carcinogenesis.

#### C.3.2.1 Electrophilicity and DNA reactivity (KC#1)

Studies informing the ability of Cr(VI), the reductive intermediates Cr(V) and Cr(IV), and the final form Cr(III) to bind DNA and proteins, forming adducts and crosslinks, are summarized in Table C-46. See Section 3.2.3.4 of the main toxicological review for a summary of the major findings, and Mezencev and Gibbons (2023) for a detailed review and analysis.

Table C-46 Mechanistic studies informing the intracellular reduction of Cr(VI) and reactivity of Cr species with DNA and proteins

Study findings | Reference
Formation and stabilization of intracellular Cr species and reactive oxygen species
Cr(V) complexes characterized by elemental analyses, electrospray mass spectrometry (ESMS), and electron paramagnetic resonance (EPR) spectroscopy. | Bartholomäus et al. (2013)
Reduction of Cr(VI) generates Cr(V), superoxide and hydroxyl radicals in purified human cytochrome b(5) and NADPH:P450 reductase in reconstituted proteoliposomes (PLs). | Borthiry et al. (2007)
Two Cr(V) electron spin resonance (ESR) signals, g = 1.979 (nonthiol dependent) and 1.985 (thiol-dependent) in human bronchial epithelial cells (BEAS-2B).; - Signals blocked by suppressing NAD(P)H | Borthiry et al. (2008)
ESR spectroscopy and electrospray mass spectrometry measured long-lived Cr(V) complexes formed by reduction of Cr(VI) with p-bromobenzenethiol (RSH). | Levina et al. (2010)
Cr-DNA adducts in acellular/in vitro test systems
DNA strand breaks in bacteriophage lambda DNA but no DNA adducts formed in calf thymus DNA with Cr(VI) and +1 mM H2O2, [^32^P] post-labeling | Adams et al. (1996)
Cr(VI) reduction by glutathione produces 2 Cr(V) complexes and glutathione thiyl radical, correlated with Cr-DNA adduct formation; no DNA strand breaks.; Cr(VI) reduction by H_2_O_2_ produces hydroxyl radical, DNA strand breaks, and 8-OHdG adducts with no Cr(V) generation. | Aiyar et al. (1989); (1990, 1991)
Cr(VI) showed weak complexation with DNA at high molar ratios of CrO_4_^2−^ to nucleotides (r > 1) but not at low molar ratios (r = 1:20 to r = 1:1). | Arakawa et al. (2000)
Calf thymus DNA and defined DNA polynucleotides. | Borges and Wetterhahn (1989)
DNA-chromium adducts cause guanine-specific arrests of DNA replication in calf thymus DNA using mammalian polymerases alpha and beta. | Bridgewater et al. (1998)
DNA-protein crosslinks in human HL-60 cells exposed to Cr(VI) | Capellmann et al. (1995)
DNA-protein crosslinks and DNA fragmentation in human bronchial epithelial cells and embryonic lung fibroblasts (IMR-90) and in mouse L1210 leukemia cells exposed to Cr(VI) | Fornace et al. (1981)
Low, nonphysiological levels of ascorbate lead to GSH reduction of Cr(VI) that produce weakly mutagenic glutathione-Cr(III)-DNA adducts and no oxidative damage in human fibroblasts. | Guttmann et al. (2008)
↑ ATM activation by Cr(VI) in ascorbate-deficient cells; no ATM activation when ascorbate levels are restored in human lung H460 cells and normal human lung fibroblasts. | Luczak et al. (2016)
DNA-protein crosslinks formed in human lung A549 (alveolar epithelial adenocarcinoma) cells in 3 steps: Cr(VI) reduction to Cr(III), Cr(III)-DNA binding, and capture of proteins by DNA-bound Cr(III). | Macfie et al. (2010)
Interstrand DNA crosslinks formed in XPA-null (GM04312), FANCD2-null (GM16633), and FANCD2-complemented (GM16634) human fibroblasts with ascorbate (1.3% of total adducts, dose-dependent) and glutathione (<1%, sublinear).; - Absence of FANCD2 and XPF-ERCC1 endonuclease produced no hypersensitivity to Cr(VI) with restored ascorbate levels; - Authors interpreted as evidence that DNA crosslinks are more commonly formed in vitro | Morse et al. (2013)
↑ ascorbate-Cr(III)-DNA crosslinks in human lung A549 (alveolar epithelial adenocarcinoma) cells with restored ascorbate levels (25% of total Cr-DNA adducts).; Ascorbate-Cr(III)-DNA crosslinks inhibited by mg^2+^ ions suggest predominant binding of ascorbate-Cr(III) to DNA through phosphate oxygen. | Quievryn et al. (2002)
Cr-DNA adducts, and not oxidative strand breaks, responsible for mutation and replication fork stalling in SV40-immortalized human HF/SV fibroblasts.; - Ternary adducts more mutagenic than binary; - Mutation spectra equally deletions and point mutations targeting G/C | Quievryn et al. (2003)
Reduction of Cr(VI) by ascorbate produced stable adducts in supercoiled ϕX174 DNA that could be disrupted only by phosphate treatment at high concentrations of ascorbate (1 mM) and not at lower concentrations of ascorbate (0.2 mM). | Quievryn et al. (2006)
Cr(III) forms adducts with DNA via formation of Cr-protein crosslinks with amino acids in intact cell cultures. | Salnikow et al. (1992)
Fanconi anemia cells (hypersensitive to DNA crosslinking agents) are hypersensitive to Cr(VI)-induced apoptosis, clonogenic lethality, and DNA DSBs (gH2AX foci). | Vilcheck et al. (2002); Vilcheck et al. (2006)
In human fibroblasts, ternary adducts glutathione-Cr(III)-DNA and histidine-Cr(III)-DNA are more mutagenic than cysteine-Cr(III)-DNA; binary Cr-DNA adducts were weakly mutagenic. | Voitkun et al. (1998)
DNA-DNA crosslinks in human lung fibroblasts exposed to Cr(VI) | (Xu et al., 1996a)
The formation of ternary complexes of glutathione or amino acids with Cr(III) and DNA were estimated to account for as much as 50% of DNA-bound chromium following exposure of CHO cells to ≤25 μM Cr(VI). | Zhitkovich et al. (1995)
Cr(VI) reduction by cysteine forms Cr-DNA and Cys-Cr-DNA adducts and interstrand DNA-DNA crosslinks that increase with Cr(VI) concentration but did not produce DNA breaks or oxidative DNA damage. | Zhitkovich et al. (2000)
In human fibroblasts, binding of Cr(III) and the formation of Cr(III)-DNA adducts induces structural distortions of DNA.; Ascorbate-Cr(III)-DNA and cysteine-Cr(III)-DNA adducts were found to be 31-fold and 5.3-fold more mutagenic than the binary Cr(III)-DNA adducts, respectively. | Zhitkovich et al. (2001)
Cysteine-dependent Cr(VI) reduction led to Cr-DNA adducts (54%), cysteine-Cr-DNA adducts (45%), and interstrand DNA crosslinks (1%). | Zhitkovich et al. (2002)
Cr(III)-DNA binding:; - To backbone phosphates through reversible electrostatic interactions; - To nucleobases with the preference G>C>T~A, generating stable crosslinks resistant to dissociation by EDTA; this binding is slow due to slow ligand exchange in Cr(III) complexes | Zhou et al. (2016)
In vivo test systems
Exposed: Four human adult volunteers; Referents: Preingestion background DNA-protein crosslink levels for each individual served as the controls; Ingestion of a single bolus dose of 5,000 μg Cr(VI) as K_2_Cr_2_O_7_ alone (Cr(VI) or reduced to Cr(III) with orange juice; approximately equivalent to 71 μg Cr(VI)/kg, assuming a body weight of 70 kg.; Blood samples were collected at 0, 60, 120, 180, and 240 min after ingestion.; - No significant changes in DNA protein cross-linking after ingestion; - Very small sample size limits confidence in the results; - The only known ingestion study in humans; all other human studies evaluate inhalation in occupational cohorts | Kuykendall et al. (1996)
Rat, Fischer 344, male, exposed to 100 or 200 mg/L K_2_Cr_2_O_7_ in drinking water, 3 or 6 wk; - ↑ DNA-protein crosslinks in liver; not in splenic lymphocytes; - No cytotoxicity detected | Coogan et al. (1991a)
Rat, exposed to 20 mg/kg Cr(VI) by i.p. injection, 40 hr; - ↑ Cr binding to DNA, nonhistone proteins, and cytoplasmic RNA-protein fraction in liver | Cupo and Wetterhahn (1985)
Rat, Sprague-Dawley, 0.25 mg/kg Na_2_Cr_2_O_7_ (0.09 mg Cr(VI)/kg) per day via intratracheal instillation, 3 d; - ↑ 8-OHdG adducts ([32P] post labeling) were detected in lung, but not liver; - ↑ DNA-protein crosslinks; - ↑ DNA fragmentation | Izzotti et al. (1998)
Rat, Sprague-Dawley, male, i.p., 20 or 50 mg/kg-d; - 1 h: DNA-DNA and DNA-protein crosslinks in liver, lung and kidney; - ↑ DNA strand breaks in liver; - 36–40 hr: DNA-protein crosslinks in lung and kidney | Tsapakos et al. (1981), Tsapakos et al. (1983)
Rat, Osteogenic Disorder Shionogi, exposed to 10 or 40 mg/kg Cr(VI) by i.p. injection; - No increase in Cr(VI) uptake, Cr(V) signal, or Cr-DNA binding in rats unable to synthesize ascorbate | Yuann et al. (1999)

#### C.3.2.2 Genotoxicity (KC#2)

##### In vivo studies

###### Inhalation route of exposure

###### Mutagenic MOA studies

Studies considered most relevant to a mutagenic MOA analysis for lung cancer are studies of occupationally or environmentally exposed humans or studies in experimental animals exposed via inhalation or intratracheal instillation and include measures of gene mutation (prior to tumorigenesis), micronuclei induction, and chromosomal aberrations. Occupational studies were considered only if they included a comparison or referent population exposed to Cr(VI) at lower levels (or no exposure/exposure below detection limits) or for shorter periods of time. Animal studies were considered if they included a concurrent control group exposed to vehicle-only treatment or an untreated control.

Thirty studies in humans occupationally exposed and one study in transgenic mice were identified. These were evaluated in HAWC using criteria specific to the mutational assay used in the study to judge the outcome ascertainment domain. The overall confidence judgments and summaries of the study findings can be found in the Cr(VI) Toxicological Review in Section 3.2.3 Cancer—Mechanistic Evidence; more extensive summaries of the human studies are in Table C-47 below. Human studies reporting other outcomes informative to genotoxicity are summarized in the following sections.

Table C-47 Chromosomal mutation studies in humans exposed to Cr(VI) via inhalation (evaluated in HAWC)

Study overview | Exposure^a^ | Results | Comments | Reference
Chromosomal aberrations
Cross-sectional study, South India.; Exposed: n = 72 (n = 36 directly exposed via work in a tannery, n = 36 indirectly exposed via residence in proximity to tanneries); Referent: n = 36 unexposed controls (“normal and healthy individuals who had not exposed themselves to any kind of chemicals or radiation”) | Assessment: Exposure to Cr(VI) inferred based on occupation and residence.; In addition, Cr was measured in urine and air samples (unclear where air samples were collected); Levels: There was a gradient in levels of both, there were detectable chromium levels in both air and urine for “controls”; Direct exposure (n = 36) (mean ± SD):; Total Cr in air (1 mg/m^3^): 0.101 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.021 ± 0.003; Cr content in urine: 2.11 ± 1.01; Indirect exposure (n = 36):; Total Cr in air (1 mg/m^3^): 0.089 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.013 ± 0.005; Cr content in urine: 1.81 ± 0.88; Controls (n = 36):; Total Cr in air (1 mg/m^3^): 0.014 ± 0.004; Cr(VI) in air (0.001 mg/m^3^): 0.006 ± 0.001; Cr content in urine: 0.54 ± 0.39; Duration: Directly exposed subjects were “selected based on the duration of their exposure (0–5; 6–10; 11–15; 16–20; 21–25 yr) and were known to be exposed to Cr(VI) for a minimum of 8 hr/d,” while indirect exposure was inferred from residence of at least 30 yr duration, “in and around the tanneries.” | ↑ chromosomal aberrations in DE group compared with IE group and controls.; Also observed ↑ mean tail length for comet assay in DE group compared with IE group and controls and ↑ MN among directly exposed subjects compared with indirectly exposed & controls; further elevated in those with longer duration of exposure | Low confidence. There is evidence of a gradient of chromium exposure across the three study groups, but inference is limited by small sample size and lack of description.; Some of the controls also had detectable chromium in urine, suggesting this is not really a true “control” group.; Concerns with chromosomal aberrations assay—culture of 72 hr may have missed first in vitro cell division.; Very limited evaluated of confounders. | Balachandar et al. (2010)
Cross-sectional study, Bulgaria.; Exposed: Chromium plate workers (n = 15); Referents 1: age, gender, smoking-matched controls (n = 15); Referents 2: individuals of similar age from unpolluted rural region (n = 8) | Assessment: Blood samples and buccal mucosal cells taken from exposed group; exposure to Cr(VI) inferred based on occupation. Also measured Cr with personal air samplers and in urine samples.; Levels: There was a gradient of chromium in air and urine across groups, although there was detectable Cr in urine of rural controls.; Mean air concentration of total chromium was 0.0075 mg Cr/m^3^ in the low-exposure group (n = 4) and 0.0249 mg Cr/m^3^ in the high-exposure group (n = 7). (4 workers in the exposed group temporarily discontinued exposures and were considered separately.); Mean concentrations of Cr in urine were 18.63 μg/L (low) and 104.22 μg/L (high).; Results reported for combined groups (0.0075 and 0.0249 mg Cr/m^3^).; Duration: Duration of exposure ranged from 2 to >20 yr; mean duration of exposure was not reported. | In exposed workers compared with referent 1:; Buccal cells:; No difference in frequencies of chromosomal aberrations or SCEs; Study also reported significantly increased MN in buccal cells and lymphocytes in referent 1 compared with referent 2 | Low confidence. Although exposed and unexposed workers were matched on age, sex, and smoking habit, the two unexposed (worker and rural) groups were combined, resulting in lower confidence in comparability of exposed and unexposed group comparisons. Inference is further limited by small sample size and lack of description.; Similar proportion of centromere-positive and - negative micronuclei indicate both clastogenic and aneugenic effects occurring. | Benova et al. (2002)
Cross-sectional study of workers at a single facility in China.; Exposed: n = 7 electroplating workers exposed to chromium; Referent: n = 10 office workers; Note: also included n = 7 electroplating workers exposed to nickel | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in personal air samples from work room, hair, and stool samples.; Levels: Authors note that there seemed to be little cross-contamination of nickel and chromium in respective work areas based on air samples, but stool samples showed similar levels of both compounds between exposure groups. Hair levels of chromium were higher in chromium compared with nickel workers. The mean chromium (total) air concentration (by random air collection) was 8.1 μg/mm^3^, the mean chromium concentration in stool samples was 8.5 μg/g stool, and the mean chromium concentration in hair was 35.68 μg/g.; (The exposure level of 8.1 μg chromium/mm^3^ is as reported by Deng et al. (1988); however, this appears to be a reporting error, as this concentration is equivalent to 8,100,000 mg chromium/m^3^.); Duration: Mean duration of occupational exposure was 12.8 yr. | ↑ chromosomal aberrations in chromium workers compared with nickel workers and controls; ↑ SCE in chromium and nickel workers compared with controls | Low confidence. Although controls were age and sex matched to exposed subjects and were stated to have similar socioeconomic status, the sample size is quite small and the analysis limited. Also unclear how well differentiated chromium exposure is by group—analyses of chromium in hair suggest a delineation with controls, but no information on stool samples that showed similarities between nickel and chromium workers. | Deng et al. (1988)
Cross-sectional study, Slovak Republic.; Exposed: n = 73 male welders; Referent: n = 71 male controls (administrative officers and hospital employees) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in blood.; Levels: Exposed workers had average values about twice as high as referent group (stated to be significantly different). Mean ± SE was 0.07 ± 0.04 vs. 0.03 ± 0.007 μMol/L.; Duration: Mean ± SD duration of occupational exposure was 10.2 ± 1.7 yr. | No differences in CAs, CTAs, and CSAs between exposed and control groups; ↑ CAs in individuals with Gln/Gln genotype compared with Arg/Gln or Arg/Arg genotypes in XRCC1 Arg299Gln; more pronounced in Cr-exposed workers | Medium confidence. Main limitations are related to lack of description (e.g., for participant selection) and lack of evaluation of confounders aside from smoking. | Halasova et al. (2012)
Cross-sectional study, Slovak Republic.; Exposed: n = 39 male welders; Referent: n = 31 male controls (source not given) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in blood.; Levels: Exposed workers had average values about twice as high as referent group. Mean ± SE was 0.07 ± 0.04 vs. 0.03 ± 0.007 μMol/L.; Duration: Mean ± SD duration of occupational exposure was 10.2 ± 1.7 yr. | No significant differences in frequencies of CTAs between exposed and control groups; only minor differences in CAs between groups; ↑ CSAs in exposed compared with control groups; ↑ CAs & CTAs in individuals with Gln/Gln genotype compared with Arg/Gln or Arg/Arg genotypes in XRCC1 Arg299Gln | Low confidence. Main limitations are related to sample size, unclear differentiation between exposure groups, and lack of description (e.g., for participant selection). | Halasova et al. (2008)
Cross-sectional study, Finland.; Exposed: n = 23 male welders; Referent: n = 22 male office employees at a printing company | Assessment: Exposure to Cr(VI) inferred based on occupation. Welders were chosen due to “exposure to MMA/SS welding fumes with little or no exposure to other agents in their occupational history.”; Also measured total Cr in urine.; Levels: Urine levels are not discussed in text (table shows values ranging from 0.20 to 1.55 μMol/L).; Duration: Welders likely had Cr(VI) exposure due to history of manual metal arc welding for at least 4 yr and most for much longer (mean ± SD = 21 ± 10 yr). | No significant differences (frequency of chromosome aberrations or SCEs) | Low confidence. Although Cr(VI) exposure seems likely to occur among these welders, the analysis is limited by small sample size when stratifying by smoking (found to be related to the outcome). | Husgafvel-Pursiainen et al. (1982)
Cross-sectional study, Japan.; Exposed: n = 51 male stainless steel welders; Referent: n = 33 male office or research workers in the same factory | Assessment: Exposure to Cr(VI) inferred based on occupation.; Total Cr also measured in urine samples.; Levels: Mean urinary Cr was 9.8 and 4.2 μg/L among exposed and referent group, respectively.; Duration: Welders had been “constantly engaged” in stainless steel welding for 5–20 yr (mean 12 yr) and thus are presumed to have high potential for Cr(VI) exposure. | ↑ chromosomal aberrations and SCEs in welder compared with controls | Low confidence. The main limitations are related to the outcome evaluation and to poorly described and reported data analysis and lack of consideration of potential confounders. | Koshi et al. (1984)
Cross-sectional study, Sweden.; Exposed: n = 24 stainless steel welders from 6 industries; Referent: n = 24 matched referents who “had no occupational (or other) experience with the handling of stainless steel (or other known mutagenic/carcino genic agents)” | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured total Cr in air (welders only) and urine (all).; Levels: Mean urinary Cr was 47 and 1.5 μMol/mol creatinine among exposed and referent group, respectively. Mean air Cr level 81 μg/m^3^.; Duration: Welders were selected for their “long and intense” welding on stainless steel (mean work duration of 19 yr). | No significant differences (frequency of breaks or fragments; gaps and isogaps; interchanges, dicentrics, rings, and markers; structural aberrations, hyperdiploidy; SCEs) | Low confidence. Main limitations are related to outcome ascertainment and statistical analysis, as well as limited description of results. | Littorin et al. (1983)
Cross-sectional study, South Korea.; Exposed: n = 51 male chrome plating and buffing workers; Referent: n = 31 male office workers from “industrial areas” in South Korea | Assessment: Exposure to Cr(VI) inferred based on occupation.; Also measured Cr in air samples (total and VI), blood, and end-shift urine samples (See Table 1).; Levels: Concentrations in blood and urine were significantly higher in exposed workers, indicating adequate delineation between groups. For example, the geometric mean blood level of Cr was 0.9 and 0.2 μg/dL in exposed and referent workers, respectively. Differently, while air measures were higher for exposed workers the difference was not statistically significant.; Duration: Mean duration of occupational exposure was 9.1 yr (range: 1 mo to 40 yr). | ↑ frequency of chromatid exchange; chromosome/chromatid breaks and exchanges; and of translocations, with higher blood Cr; ↑ frequency of translocations in exposed compared with unexposed. | Low confidence. Main limitations are related to lack of description for analysis and results reporting. | Maeng et al. (2004)
Cross-sectional study, Italy.; Exposed: n = 38 male plating factory workers (two groups from factories using nickel and chromium for bright plating, and two groups from factories using only chromium for hard plating); Referent: n = 35 “healthy male sanitary workers” not known to have chromium exposure; Note: Analysis of SCEs only included n = 21 workers from factories using only chromium, and n = 14 “healthy blood donors” with similar selection as unexposed worker control group | Assessment: Exposure to Cr(VI) inferred based on occupation. Exposed group was stratified based upon coexposure to nickel (“bright” plating, vs. “hard” plating).; Also measured Cr in urine.; Levels: Urinary Cr levels were lowest in controls (mean ± SD = 1.9 ± 1.4 μg/g crt), intermediate in bright plating (6.1 ± 2.8 μg/g crt), and highest in hard plating groups (10.0 ± 7.5 μg/g crt), indicating adequate delineation between groups.; Duration: Mean (SD) yr of exposure: bright plating = 9 (11); hard plating = 7 (3) | ↑ frequency of total aberrations, chromosome-type aberrations in all exposed.; Also ↑ chromatid-type aberrations in bright platers.; ↑ SCEs for some worker compared with blood donors. | Low confidence. Main limitations are related to outcome ascertainment, small sample size for certain analyses, and lack of description (e.g., for participant selection and statistical analysis). | Sarto et al. (1982)
Micronuclei
Cross-sectional study, South India.; Exposed: n = 72 (n = 36 directly exposed via work in a tannery, n = 36 indirectly exposed via residence in proximity to tanneries); Referent: n = 36 unexposed controls (“normal and healthy individuals who had not exposed themselves to any kind of chemicals or radiation”) | Assessment: Exposure to Cr(VI) inferred based on occupation and residence. In addition, Cr was measured in urine and air samples (unclear where air samples were collected); Levels: There was a gradient in levels of both urine and air, there were detectable chromium levels in both air and urine for “controls.”; Direct exposure (n = 36) (mean ± SD):; Total Cr in air (1 mg/m^3^): 0.101 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.021 ± 0.003; Cr content in urine: 2.11 ± 1.01; Indirect exposure (n = 36):; Total Cr in air (1 mg/m^3^): 0.089 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.013 ± 0.005; Cr content in urine: 1.81 ± 0.88; Controls (n = 36):; Total Cr in air (1 mg/m^3^): 0.014 ± 0.004; Cr(VI) in air (0.001 mg/m^3^): 0.006 ± 0.001; Cr content in urine: 0.54 ± 0.39; Duration: Directly exposed subjects were “selected based on the duration of their exposure (0–5; 6–10; 11–15; 16–20; 21–25 yr) and were known to be exposed to Cr(VI) for a minimum of 8 h/d” while indirect exposure was inferred from residence of at least 30 yr duration, “in and around the tanneries.” | ↑ micronuclei peripheral lymphocytes among directly exposed subjects compared with indirectly exposed & controls; and further elevated in those with longer duration of exposure | Low confidence. There is evidence of a gradient of chromium exposure across the three study groups, but inference is limited by small sample size and lack of description.; Some controls also had detectable chromium in urine, suggesting this is not really a true “control” group.; Very limited evaluation of confounders. | Balachandar et al. (2010)
Cross-sectional study, Bulgaria.; Exposed: Chromium plate workers (n = 15); Referents 1: age, gender, smoking-matched controls (n = 15); Referents 2: individuals of similar age from unpolluted rural region (n = 8) | Assessment: Blood samples and buccal mucosal cells taken from exposed group; exposure to Cr(VI) inferred based on occupation. Also measured Cr with personal air samplers and in urine samples.; Levels: There was a gradient of chromium in air and urine across groups, although there was detectable Cr in urine of rural controls.; Mean air concentration of total chromium was 0.0075 mg Cr/m^3^ in the low-exposure group (n = 4) and 0.0249 mg Cr/m^3^ in the high-exposure group (n = 7). (4 workers in the exposed group temporarily discontinued exposures and were considered separately.); Mean concentrations of Cr in urine were 18.63 μg/L (low) and 104.22 μg/L (high).; Results reported for combined groups (0.0075 and 0.0249 mg Cr/m^3^).; Duration: Duration of exposure ranged from 2 to >20 yr; mean duration of exposure was not reported. | ↑ micronuclei per peripheral blood leukocytes (PBLs) & ↑ overall number of PBLs with micronuclei in exposed workers compared with controls; ↑ micronuclei in buccal cells in exposed workers compared with controls; No significant difference between proportion of C+ and C− micronuclei in buccal or PBLs in exposed workers compared with controls | Low confidence. Positive results reported for combined groups (0.0075 and 0.0249 mg chromium/m^3^).; Although exposed and unexposed workers were matched on age, sex, and smoking habit, the two unexposed (worker and rural) groups were combined, resulting in lower confidence in comparability of exposed and unexposed group comparisons. Inference is further limited by small sample size and lack of description. | Benova et al. (2002)
Cross-sectional study, India.; Exposed: n = 102 male welders; Referent: n = 102 male controls selected from the general population “with no history of exposure to welding fumes or any known physical or chemical agent in the workplace, but belonged to the same age group and socioeconomic status as the welders.” | Assessment: Exposure to Cr(VI) inferred based on occupation. Welders used shielded metal arc welding and were working with stainless steel electrodes. Also measured Cr in blood for a sample (~50%) of subjects.; Levels: Welders had much higher chromium compared with controls, indicating delineation of exposure. Mean Cr was 151.65 and 17.86 μg/L in exposed and referent, respectively.; DNA damage was measured by comet assay in all 204 subjects; frequency of micronuclei was measured in 58 welders and 53 controls.; Duration: The duration of exposure varied widely (range: 1–24 yr). (Overall mean not presented) | In buccal cells of exposed welders compared with referent:; ↑ micronuclei (p < 0.001); correlated with duration of work (p = 0.0001), age (p = 0.007), and Cr level in blood | Low confidence. Limitations related to outcome evaluation, such as the use of outdated methods no longer recommended, could lead to inaccurate scoring. A description/details on participant selection (e.g., concern for potential selection bias) is lacking.; Study also reported ↑ mean comet tail length in whole blood cells (p < 0.001). | Danadevi et al. (2004)
Cross-sectional study, Egypt.; Exposed: n = 41 male electroplating workers exposed to chromium and nickel; Referent: n = 41 male administrative workers at the same facility | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr (and nickel) in serum.; Levels: Serum Cr significantly higher in exposed compared with controls. Mean Cr was 3.30 and 0.23 μg/L in exposed and referent, respectively.; Duration: Exposed workers were required to have worked in electroplating section at least 2 yr, but most worked for considerably longer with mean ± SD = 26.68 ± 11.21 yr. | In buccal cells of exposed electroplaters compared with referent:; ↑ micronucleus induction (p < 0.001); ↑ serum Cr correlates with ↑ micronuclei (p < 0.05) | Medium confidence. Exposed and unexposed groups are delineated, although limited description of methods (e.g., participant selection) and known coexposure to nickel could limit inference.; Study also reported ↑ serum 8-OHdG. | El Safty et al. (2018)
Cross-sectional study, China.; Exposed: n = 87 workers from a single factory in China, who had “occupational exposure to chromate from different work sections”; Referent: n = 30 working in administrative offices without chromate exposure | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured total Cr in air samples and in blood.; Levels: Authors state “The concentration of Cr in the air and blood of subjects in the exposure group were significantly higher than the control group (p < 0.001),” which increases confidence in delineation of exposure groups. Geometric Mean ± SD of Cr in blood was 8.5 ± 1.3 μg/L in exposed vs. 4.1 ± 1.4 μg/L in referent group, while median (IQR) of air concentrations were 15.5 (19.0) vs. 0.2 (0.4) mg/m^3^.; Duration: Median duration of employment was 5 yr in both exposed and referent. | ↑ MN in peripheral lymphocytes in exposed workers compared with referent | Medium confidence. Main limitations are related to lack of description (e.g., for participant selection).; Study also reported ↑ hypermethylation of CpG sites and 8-OHdG adducts. | Hu et al. (2018) Related studies: (Li et al., 2014a); Li et al. (2014b)
Exposed 1: male welders working in areas without collective protections (n = 27); Exposed 2: male welders working in locations with smoke extraction systems (n = 33); Referents: office workers with no history of occupational exposure to welding fumes or other physical/chemical agent in workplace (n = 30) | Assessment: Exposure to Cr(VI) inferred based on occupation.; Also measured total Cr in blood and urine.; Levels: Cr levels in blood and urine were higher among both groups of welders compared with controls (means 129 to 145, compared with 92 μg/L), and urinary chromium was higher among welders working without smoke extraction systems.; Duration: Welders exposed for 0.5–45 yr | ↑ mean BN % in lymphocytes of welder compared with controls | Low confidence. Main limitations are related to lack of description (e.g., for participant selection, analysis), unknown contribution of Cr(VI) to Cr exposure (states that <5% of welding was done on stainless steel, which raises concern that total Cr measured in blood and urine may be attributed to Cr(III) exposure) and known coexposures to other metals. | Iarmarcovai et al. (2005)
Cross-sectional study, China.; Exposed: n = 29 “healthy” chrome platers employed for at least 1 yr at two facilities; Referent: n = 29 subjects “randomly selected from the healthy workers in the same enterprises and been engaged in public security, support services, or administration work for more than 1 yr, and had no specific chromate exposure history” | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in blood.; Levels: Blood Cr levels were significantly higher among exposed compared with unexposed workers, indicating adequate delineation between groups. Mean (range) values were 15.2 (2.1, 42) in exposed vs. 4.6 (0.2, 28) in referent group.; Duration: Chrome platers had been employed for at least 1 yr. | ↑ micronuclei frequencies in peripheral lymphocytes of Cr-exposed workers compared with controls, but no correlation between blood Cr concentration and micronuclei | Low confidence. Limitations are the limited and poorly described statistical analysis and limited description (e.g., for participant selection). Small sample size.; Inconsistent results could indicate the influence of other occupational hazards on micronuclei concentrations. | Linqing et al. (2016)
Cross-sectional study, China.; Exposed: n = 120 chromate-exposed workers working at a chromate production facility; Referent: n = 97 unexposed workers at same facility (“without contact history of harmful substances”) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in whole blood.; Levels: Cr levels were significantly higher among exposed compared with controls, indicating delineation of exposure. Median (interquartile range) of Cr in whole blood was 2.81 (3.86) and 0.99 (1.21) μg/L in exposed and referent groups, respectively.; Duration: Mean (SD) yr of exposure in chromate group = 14.57 (5.85). | ↑ MN frequency ratio in lymphocytes of exposed; results of exposure-SNP interaction on MN presented as well | Medium confidence. Main limitations are related to lack of description (e.g., for participant selection and statistical analysis). | Long et al. (2019)
Cross-sectional study, Portugal.; Exposed 1: n = 5 stainless steel welders exposed to Cr(VI); Exposed 2: n = 33 tannery workers exposed to Cr(III); Referent: n = 20–30 unexposed controls (“not known to be exposed to either environmental or occupational carcinogens”) | Assessment: Exposure to Cr(VI) inferred based on occupation.; Also measured Cr in plasma and in urine (mid-shift for welders).; Levels: Urinary and plasma chromium levels were higher in both exposed groups compared with controls. For example, mean ± SD levels in plasma were 2.43 ± 2.11 in tanners, 1.55 ± 0.67 in welders, and 0.41 ± 0.11 μg/L.; Duration: Not reported | ↑ micronuclei in lymphocytes among tanners compared with control group; (there was also a marginal increase in the welders group, but not statistically significant) | Low confidence. Main limitation is small number of welders, lack of description for participant selection, analysis, and confounders.; Study also reported ↑ formation of DNA protein crosslinks in welders compared with controls. | Medeiros et al. (2003)
Cross-sectional study, Italy.; Exposed: n = 17 tannery finishing workers with potential exposure to Cr(VI); Referent (2 groups): n = 21 and n = 17 workers “from different industries”; Note: also evaluated n = 21 tannery workers with potential exposure to Cr(III) | Assessment: Exposure to Cr(VI) inferred based on occupation. State that tannery finishing workers had potential for exposure to Cr(VI) but with no supporting description or evidence. Although unclear from the text, workers might have been from several different tanneries with differing potential for exposure to Cr(VI) containing dyes.; Levels: Not reported; Duration: Not reported | No significant associations | Low confidence. Main limitation is unclear potential for Cr(VI) exposure for tannery finishing workers. | Migliore et al. (1991)
Cross-sectional study, Brazil.; Exposed: n = 50 male chrome platers exposed to Cr(VI); Referent: n = 50 male unexposed controls | Assessment: Cr measured in whole blood and in urine.; Levels: Concentrations of Cr in both blood and urine were significantly higher in exposed compared with unexposed. Mean ± SD levels in blood for exposed and unexposed were 2.02 ± 0.20 and 1.73 ± 0.16 μg/L, respectively; levels in urine were 10.65 ± 5.26 and 4.05 ± 3.78 μg/g creatinine, respectively.; Duration: At least 1 yr of Cr(VI) exposure for exposed workers; Mean ± SD of 6.97 ± 7.35 yr duration | In buccal cells, no significant difference in MN between exposed and non-exposed group (p < 0.05) | Low confidence. Main limitations are related to outcome ascertainment, lack of description (e.g., for participant selection) and biomarker evidence of coexposure to other metals; exposed workers had significantly higher blood levels of Pb, As, Ni and V.; Study also reported ↑ DNA damage measured by the comet assay in exposed workers | Muller et al. (2020)
Cross-sectional study, India.; Exposed: n = 100 male electroplaters exposed to Cr(VI) and nickel. Group II: exposed <10 yr, n = 50; Group III: exposed for ≥10 yr, n = 50; Referent: n = 50 unexposed controls (Group I) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in plasma.; Levels: Concentrations were significantly higher in exposed (and higher for longer exposed) workers compared with unexposed. Mean + SD levels for longer exposed and shorter exposed workers were 2.9 + 0.8 and 1.7 + 0.55 μg/L, respectively, while values for referent were 0.55 + 0.08 μg/L.; Duration: Group II exposed 1–9 yr; Group III exposed 10–25 yr. | In buccal cells of Group II compared with Group I, and in Group III compared with Group II:; ↑ micronucleus frequency (p < 0.05), correlated with Cr levels in plasma (p < 0.01) | Low confidence. Main limitations are related to outcome ascertainment, limited statistical analysis, and lack of description (e.g., for participant selection). Coexposure to nickel is also a concern.; Study also reported ↑ nuclear anomalies (karyorrhexis, karyolysis, pyknosis) (p < 0.05). | Qayyum et al. (2012)
Cross-sectional study, India.; Exposed: n = 66 welders; Referent: n = 60 controls (“selected from the general population with no history of occupational exposure to welding fumes or any known physical or chemical agent in the workplace, but belonged to the same age group and socioeconomic status as the welders”) | Assessment: Exposure to Cr(VI) inferred based on occupation. State that welders were engaged in SMA welding, working with electrodes containing 20% chromium.; Levels: Not reported.; Duration: Duration of welding ranged from 5 to 20 yr. | In buccal cells of exposed welders compared with referent:; ↑ micronucleus frequency and mean comet tail length (DNA damage) that increased with duration of work (p < 0.05) | Medium confidence. The overall sample size is adequate but might not be sufficient for analyses stratified by smoking and alcohol consumption (and might need to consider both simultaneously). Potential for chromium exposure seems high given occupational context, but lack of measurements in environmental or biological media are lacking. | Sudha et al. (2011)
Cross-sectional study, Bulgaria.; Exposed 1: n = 30 male workers at a hydraulic machinery plant. Of these, n = 16 had low level exposure to chromium (various occupations, did not work close to electroplating tanks), while n = 14 had higher exposure to chromium due to work as electroplaters; Exposed 2: n = 10 hospitalized electroplaters from different plants were recruited from an occupational health clinic; Referent 1: n = 5 male administrative workers from the hydraulic machinery plant; Referent 2: n = 13 administrative workers (workplace not described) | Assessment: Exposure to Cr(VI) inferred based on occupation. The workers were split into two groups based on levels of exposure.; Also measured Cr in air, erythrocytes, and urine for exposed workers only.; Levels: Mean air chromium (total) concentrations were 43 and 83 μg/m^3^ in the low- and high-exposure groups, respectively. Mean chromium concentrations in erythrocytes and urine of the low-exposure group were 4.31 and 3.97 μg/L, respectively. The mean chromium concentrations in erythrocytes and urine of the high-exposure group were 8.4 and 5.0 μg/L, respectively.; Duration: Duration of employment ranged from 4 to 25 yr with mean durations of 10.44 and 11.63 yr in the low- and high-exposure groups, respectively. | ↑ MN and binucleated cells carrying MN in lymphocytes of exposed compared with control; also found correlations of Cr measured in air, erythrocytes and urine, with higher MN. | Low confidence. Limitations are due to small sample size, questionable pooling of various exposed and control groups, lack of consideration of confounding, and limited description of analysis. | Vaglenov et al. (1999)
Cross-sectional study, Austria.; Exposed: n = 22 bright chrome plating workers exposed to chromium and cobalt; Referent: n = 22 jail wardens | Assessment: Exposure to Cr(VI) inferred based on occupation. Welders used mainly TIG process (95%) with smaller proportions of electric arc and very little autogenous welding. Also measured Cr in whole blood.; Levels: Blood levels were higher in welders compared with controls. Mean + SD levels for exposed workers at the beginning and end of the work week were 1.4 + 0.9 and 2.3 + 1.5 μg/L, respectively, while values for referent were 0.2 + 0.2 μg/L; Duration: All welders worked 8 h/d, 3 wk before and during the collection of the samples. | In exfoliated cells of exposed chrome platers compared with referent:; Buccal cells: ↑ micronucleus frequency by 23% that was not quite statistically significant (p = 0.516); Nasal cells: ↑ micronucleus frequency by 97% (p = 0.005); ↑ nuclear anomalies in both cell types | Low confidence. Limitations are due to small sample size and presence of coexposures, which precluded more detailed analysis to separate effects. | Wultsch et al. (2014)
Cross-sectional study, China; Exposed: n = 79 chromate production workers; Referent: n = 112 peasant volunteers without occupational chromate exposures | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in blood, urine, and air.; Levels: Concentrations were higher in all media among exposed (mean (range); air: 13.01 (1.03–56.60) μg/m^3^; blood: 9.19 (1.17–51.88) μg/L; urine: 17.03 (2.78–97.23) μg/g) creatinine compared with controls (air: 0.073 (0.023–0.235) μg/m^3^; blood: 3.44 (0.25–22.51) μg/L; urine: 1.42 (0.39–26.82) μg/g.; Duration: Mean (SE) yr of work among chromate group = 14.89 (8.65). | ↑ MN in binucleated cells among exposed compared with control group. Moderate correlations (0.353–0.517) between Cr in blood, urine, air, and MN | Low confidence. Limitations include unclear recruitment processes (leaving potential for selection bias), potential exposure to chromium in control group reducing sensitivity, and limited analysis (including unclear approach to address confounding). | Xiaohua et al. (2012)

The following studies were found to be uninformative due to critical deficiencies in the exposure or outcome domain: Littorin et al. (1983), Sarto et al. (1990), Cid et al. (1991), Huvinen et al. (2002a), Hilali et al. (2008), Sellappa et al. (2010), Coelho et al. (2013), and Wultsch et al. (2017).

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

###### Supporting genotoxicity studies in lung tissue

In addition to the studies measuring gene and chromosomal mutation summarized above, other mechanistic evidence investigating genotoxicity specific to lung tissues following exposures to Cr(VI) was identified in preliminary title and abstract screening. These studies were tagged as “mechanistic” and further screened and tagged as “inhalation” and “cancer” if they were epidemiological studies of humans exposed to Cr(VI) via inhalation or studies conducted in lung tissues or cells that were relevant to carcinogenic processes. Four additional genotoxicity studies of lung tumor tissue in occupationally exposed humans were identified. Genotoxicity evidence from in vitro studies conducted in human primary or immortalized lung cells examining genotoxicity endpoints relevant to lung cancer are also summarized below. The evidence is summarized in Table C-48.

Table C-48 Supporting genotoxicity studies in lung tissues and cells following Cr(VI) exposures

Study overview | Exposure^a^ | Results | Comments | Reference
Gene mutation or gene expression in tumor tissue
20 lung tumor & normal tissue samples from 19 individuals undergoing surgery for lung cancer or at autopsy | Assessment: Based on occupation; Levels: Not reported; Duration: Male workers exposed to chromate for average 21.7 ± 9.1 (8–38) yr | P53 mutations found in 4 (20%) of 20 chromate-exposed lung samples.; ↓ occurrence of p53 mutations in chromate exposed workers; Key differences in chromate exposed workers: no G-to-T transversions; 50% point mutations had changes in AT base pairs; 50% of those with point mutations had double missense mutations | P53 mutations in chromate-exposed workers with lung cancer; the pattern of p53 mutations in lung cancer patients exposed to chromate differed from that of common lung cancers in 3 respects.; No adjustments for potential confounders; no information on smoking provided; small sample size; limited information on selection. | Kondo et al. (1997)
Exposed 1: exocrine pancreatic cancer cases with K-ras mutated tumors (n = 83); Exposed 2: exocrine pancreatic cases without K-ras mutated tumors (n = 24) | Assessment: Finnish job-exposure matrix (Finjem): Inhalation exposure to chromium dust or fumes from welding, smelting, grinding, or related processing of steel or other materials containing chromium (including metallic chromium, Cr(III), Cr(VI), and other chromium compounds); Industrial hygiene evaluation: inhalation and dermal exposure to Cr(III) and Cr(VI); Levels: Not reported; Duration: Not reported | ↑ OR of K-ras codon 12 mutated pancreatic cancer with inhalation exposure to chromium; ↑ proportion of glycine to valine mutations (G-to-T transversions) with inhalation exposure to chromium | PCR-RFLP analysis of formalin-fixed and paraffin-embedded tumor specimens for point mutations at codon 12 of the K-ras gene.; Very few individuals actually exposed to Cr; wide confidence intervals indicate model instability. | Alguacil et al. (2003)
Exposed: Chromium workers diagnosed with lung cancer (n = 67 males); Referent: male controls with lung cancer but without known exposure to chromium (n = 104) | Assessment: Total and hexavalent Cr measured in soil and air samples taken “in the vicinity of the workplace” using atomic absorption spectrometry; Levels: Mean values of Cr(VI) in air of smelting plants were 0.019–0.03 mg/m^3^. Soil chromium had a value of 137 mg/kg.; Duration: Mean exposure time 16.7 ± 10.0 (SD) yr (range 1–41 yr) | In lung cancer tissues (preserved in paraffin blocks):; ↓ surviving (anti-apoptotic); ↑ p53 (pro-apoptotic) | The information regarding potential exposure is sparse. There were also differences in the type of lung cancer between exposed and referent which may impact results. No information on smoking, which could be important to consider given all participants had lung cancer.; In addition, P53 detection by IHC is nonspecific and will include nonfunctional P53 protein. | Halasova et al. (2010)
Exposed: lung cancer specimens from ex-chromate workers (n = 19); Referents 1: lung cancer specimens from individuals never exposed to chromate, silica, or other occupational compounds (n = 52); Referents 2: lung cancer specimens from nonasbestos pneumoconiosis (n = 63) | Assessment: Based on occupational history; Levels: Not reported; Duration: Not reported | In lung cancer tissues (squamous cell carcinomas) from chromate-exposed patients compared with nonexposed or pneumoconiosis patients:; ↑ cyclin D1 expression (p < 0.001); No difference in bcl-2 or p53 expression | No assessment of exposure; reliance on work history alone.; Minimal details on case/control selection.; No consideration of confounders, except smoking status. | Katabami et al. (2000)
Mouse, transgenic C57BL/6 Big Blue® mice | Intratracheal instillation (single administration): 0, 1.7, 3.4, or 6.8 mg/kg Cr(VI); Measured mutation frequency in lung at 1, 2, or 4 wk postexposure | Significantly increased mutation frequency at all doses; increased with dose and duration posttreatment; Mutation spectrum: increased frequency of G:C to T:A transversions, associated with oxidative damage | Preliminary experiment identified doses >6.75 mg/kg were lethal.; Potentially underpowered with 4 mice per dose group.; Positive control not concurrently tested with Cr(VI)-treated group.; Inconsistent/low numbers of PFUs scored per animal.; Spontaneous mutations primarily G:C to A:T transitions. | Cheng et al. (1998); (2000)
In vitro genotoxicity in primary and immortalized human lung cells
A549 (human alveolar epithelial adenocarcinoma) | 10 μM K_2_CrO_4_, 1–24 hr | Distribution of bulky DNA adducts and oxidative DNA damage and mutational signature of p53 mutations following exposure to Cr(III), Cr(VI), and Cr(V). | | Arakawa et al. (2012)
HLF human lung fibroblasts (LL-24 cell line) | 3, 6, and 9 μM Na_2_CrO_4_, 24 hr | ↑ Cr-DNA adducts | Pretreatment with 1 mM ascorbate or 20 μM tocopherol had no ameliorative effects.; Also ↑ cytotoxicity, duration- and dose-dependent (stat. sig. ≥6 μM).; ↑ apoptosis; ↑ p53 (4- to 6-fold) | Carlisle et al. (2000a)
A549 (human alveolar epithelial adenocarcinoma) and BEAS2B (human bronchial epithelial) cells | 0.1, 0.5, 1.0, and 10 μM Na_2_CrO_4_, 0.5, 1, and 4 hr | ↑ oxidative DNA damage (Fpg-modified comet assay) | Oxidative role in DNA damage decreased with time at lower Cr(VI) concentrations and increased with time at higher concentrations.; A549 more sensitive than BEAS2B.; Also ↑ apoptosis at 10 μM (caspase-3 activity and morphology). | Cavallo et al. (2010)
H460 human lung epithelial cells, IMR90 normal human lung fibroblasts, and normal mouse embryonic fibroblasts | 0, 5, 10, 15, and 20 μM K_2_CrO_4_ | DNA damage response to Cr(VI)-induced DNA double-strand breaks (phosphorylation of γH2AX) dependent on ATR kinase and not ATM in ascorbate-restored cells; DNA DSBs only formed in euchromatin | Involvement of ATR and DSBs forming in actively transcribed regions increases the probability that Cr(VI) can generate carcinogenic mutations. | Deloughery et al. (2015)
Human bronchial epithelial cells and IMR-90 embryonic lung fibroblasts | K_2_CrO_4_ or K_2_Cr_2_O_7_, 25–200 μM, 1–12 hr | ↑ DNA-protein crosslinks, dose-dependent, persistent at 12 h; ↑ DNA fragmentation, resolved at 4 h | Crosslinking assumed to partially obscure SSB levels; Same result in mouse L1210 leukemia cells | Fornace et al. (1981)
A549 human alveolar epithelial adenocarcinoma cells | 10–500 μM Na_2_Cr_2_O_7_, 1 or 16 hr | ↑ DNA strand breaks, dose-dependent (comet assay) that were 10× higher with FAPY; ↑ 8-OHdG | Authors conclude that Cr(VI)-induced oxidative DNA damage might partly be due to a reduced capacity to repair endogenous and Cr(VI)-induced 8-OHdG lesions.; Also ↓ OGG1 mRNA, dose-dependent (RT-PCR and RNase protection assay); not affected by adding H_2_O_2_.; No effect on hAPE or GAPDH. | Hodges et al. (2001); Hodges and Chipman (2002)
HeLa and human lung bronchial epithelial cells | 0.25 μM Na_2_CrO_4_, 30 d, or 10 μM, 16 or 48 hr | ↑ chromosomal aberrations with acute or chronic exposures | Chromosomal instability caused in part by suppressed activation of BubRl and expression of Emi1, causing activation of APC/C, following nocodazole-induced mitotic arrest activation. | Hu et al. (2011)
Human U2OS osteosarcoma cells, Werner syndrome (WS) skin fibroblasts (AG03141), WI-38 fetal lung fibroblasts, telomerase-immortalized cell lines (hTERT GM01604, (hTERT AMIE15010, AG03141, hTERT BJ skin fibroblasts) | 0–4 μM Cr(VI), 6–48 hr | ↑ γH2AX foci in S-phase; ↑ WRN colocalization at γH2AX foci; ↑ telomere defects exacerbated by lack of telomerase; Lack of WRN slowed Cr(VI)-induced DNA DSB repair | Cr(VI) induces DNA DSBs and stalled replication forks; WRN helicase plays a role in the cellular recovery from Cr(VI)-induced replicative stress. | Liu et al. (2009, 2010a)
A549 (human alveolar epithelial adenocarcinoma) and BEAS2B (human bronchial epithelial) cells | 0, 0.5, 1, 2, 3, 5 μM Cr(VI), 2–72 hr | ↓ Gene 33 (Mig6, ERRFI1), dose- and time-dependent (≥1 μM, 24 h); reversed by NAC; ↑ DNA DSBs (γH2AX), dose-dependent (≥2 μM); Suppression of Gene 33 increases DNA damage (γH2AX, micronuclei) and cell transformation | Cr(VI) suppresses Gene 33, inhibiting the Cr(VI)-induced DNA damage response mediated in part by Gene 33-induced cell signaling pathways. | Park et al. (2016)
Human alveolar epithelial adenocarcinoma A549 and colon HCT116 (MLH−/−) and DLD1 (MSH6−/−) cells | 1–20 μM K_2_CrO_4_, 3–12 hr | ↑ survival, ↓ apoptosis in mismatch repair (MMR)-deficient cells; ↑ DNA DSBs (γH2AX) and apoptosis in MMR-proficient cells, dose-dependent; γH2AX foci occur in G2, but no G2 cell cycle arrest; No p53 induction in either cell type at subtoxic levels | MMR responsive to Cr-DNA adducts, not oxidative damage or crosslinks.; In MMR+ cells, apoptosis induced by Cr-DNA adducts independently of p53. | Peterson-Roth et al. (2005); Zhitkovich et al. (2006)
S-9 fraction from pulmonary alveolar macrophages or S-12 fraction of peripheral lung parenchyma of human patients | 10–30 μg sodium dichromate dihydrate per plate | ↓ mutagenicity in the Ames assay when Cr(VI) was preincubated with lung fractions | | Petrilli et al. (1986), De Flora et al. (1987b) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=1236062)
Primary human lung IMR90 fibroblasts, H460 human lung epithelial cells, and XPA- and XPF- human fibroblasts | 1–5 μM K_2_CrO_4_, 3 hr | Cr-DNA adducts are substrate for nucleotide excision repair (NER); ↑ mutagenicity of these adducts (dose-dependent) and ↑ apoptosis with NER deficiency | NER efficiently removes Cr-DNA adducts. | Reynolds et al. (2004)
Human colon HCT116 (MLH1−/−) and DLD1 (MSH6−/−), lung epithelial H460, and lung fibroblast IMR90 cell lines | 2–10 μMol/L K_2_CrO_4_, 3 hr | Ternary ascorbate-Cr-DNA adducts are substrate for error-prone mismatch repair (MMR) MSH2-MSH6 dimer, leading to ↑ DNA DSBs and ↑ apoptosis.; Cells deficient in MMR have higher survival and lower DNA DSBs | Colon cells deficient in MMR have increased survival following Cr(VI) exposures, increasing probability of clonal selection of these cells. | Reynolds et al. (2009)
Primary human lung IMR90 fibroblasts; H460 human lung epithelial cells | 0.2–8 μM K_2_CrO_4_, 3 hr | ↑ DNA DSB with ascorbate caused by aberrant mismatch repair, dose dependent.; ↑ cytotoxicity and apoptosis with ascorbate; effects reversed by suppressing DNA mismatch repair but p53 status had no effect.; ↑↑ cytotoxicity and cell cycle delay in cells deficient in oxidative DNA damage repair (XRCC1 knockdown); effects reversed by ascorbate.; Chromosomal aberrations not affected by XRCC1 status | By restoring intracellular ascorbate to physiological levels via DHA (max intracellular 0.9 mM), it was shown that ascorbate can suppress Cr(VI)-induced oxidative damage but promotes Cr-DNA lesions that are either repaired by mismatch repair, independently of p53, or lead to cytotoxicity and apoptosis. | (2007; Reynolds and Zhitkovich, 2007; 2012);
Primary human bronchial epithelial cells; p53+ and p53− H358 bronchoalveolar carcinoma isogenic cells | 200 μM K_2_CrO_4_, 2 hr | ↑ DNA strand breaks; ↑ apoptosis in p53+ cells; Apoptosis mediated by p53-upregulated modulator of apoptosis (PUMA), BAX, cytochrome C and caspase-3 | | Russo et al. (2005)
Primary human bronchial fibroblasts (PHBFs) | 1–10 μM Na_2_CrO_4_, 24 hr | Relative survival of 74% (1 μM), 57% (2.5 μM), 13% (5 μM) and 0% (10 μM); Chromosomal damage in 18% (1 μM) and 33% (2.5 μM) of metaphases | | Wise JP et al. (2002)
Human bronchial epithelial cells (16-HBE) | | ↓ cell viability, dose-dependent | Cr(VI) altered protein expression involved in apoptosis, cytoskeletal structure, and energy metabolism | Xia et al. (2022)
Human SV40 transformed fibroblasts, Werner syndrome fibroblasts, primary human lung IMR90 fibroblasts, and human colon HCT116 MLH1−/− and MLH1+ cells | 0–30 μM K_2_CrO_4_, 3 hr | ↑ nuclear relocalization of WRN in response to Cr(VI); ↓ cell survival, ↑ DNA DSBs and ↓ RAD51 foci in cells lacking WRN; ↓ DNA DSBs in cells lacking mismatch repair | Error-prone mismatch repair of Cr-DNA adducts generates DNA DSBs and repair of persistent DNA DSBs is dependent on WRN helicase. | Zecevic et al. (2009)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

###### Supporting inhalation exposure genotoxicity studies

Another set of genotoxicity studies was identified that was informative for interpretations of genotoxic risk in humans but did not specifically measure genotoxicity in lung tissues. These studies were also identified in preliminary title and abstract screening as “mechanistic” and were further screened and tagged as “inhalation,” “cancer,” and “genotoxicity” if they were epidemiological studies of humans or experimental animal studies exposed to Cr(VI) via inhalation that measured genotoxicity endpoints. After removal of endpoints already considered that reported gene and chromosomal mutation measures and studies specific to lung tissues (see above), 30 genotoxicity studies of humans occupationally exposed and 1 study in animals exposed via intratracheal instillation were identified. The evidence is summarized in Table C-49.

Table C-49 Supporting genotoxicity studies in humans and animals exposed to Cr(VI) via inhalation or intratracheal instillation

Study overview | Exposure^a^ | Results | Comments | Reference
DNA strand breaks
Exposed 1: directly exposed (DE) to Cr(VI) for >8h/d in tannery industry (n = 36); Exposed 2: indirectly exposed (IE) to Cr(I) for >30 yr based on residence near tannery industry (n = 36); Referents: age-matched controls, unexposed to chemicals or radiation (n = 36) | Assessment: Exposure to Cr(VI) inferred based on occupation and residence.; In addition, Cr was measured in urine and air samples (unclear where air samples were collected).; Levels: There was a gradient in levels of both, there were detectable chromium levels in both air and urine for “controls.”; Direct exposure (n = 36) (mean ± SD):; Total Cr in air (1 mg/m^3^): 0.101 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.021 ± 0.003; Cr content in urine: 2.11 ± 1.01; Indirect exposure (n = 36):; Total Cr in air (1 mg/m^3^): 0.089 ± 0.003; Cr(VI) in air (0.001 mg/m^3^): 0.013 ± 0.005; Cr content in urine: 1.81 ± 0.88; Controls (n = 36):; Total Cr in air (1 mg/m^3^): 0.014 ± 0.004; Cr(VI) in air (0.001 mg/m^3^): 0.006 ± 0.001; Cr content in urine: 0.54 ± 0.39; Duration: Directly exposed subjects were “selected based on the duration of their exposure (0–5; 6–10; 11–15; 16–20; 21–25 yr) and were known to be exposed to Cr(VI) for a minimum of 8 h/d” while indirect exposure was inferred from residence of at least 30 yr duration, “in and around the tanneries.” | ↑ mean tail length for comet assay in DE group compared with IE group and controls | Some of the controls also had detectable chromium in urine, suggesting this is not really a true “control” group.; Very limited evaluation of confounders.; Small sample size.; Study also reported ↑ CAs & MN in DE group compared with IE group and controls. | Balachandar et al. (2010)
Exposed: male welders (n = 102); Referents: male general population controls (n = 102), age and SES-matched to exposed | Assessment: Blood samples from 51 welders & 49 controls, selected randomly, on 4th d of the work week. Cr and Ni content measured with ICP-MS.; Levels: Welders had higher Cr and Ni compared with controls [(Cr, 151.65 versus 17.86 mg/L; Ni, 132.39 versus 16.91 mg/L; p < 0.001)].; Duration: The duration of exposure varied widely (range: 1–24 yr). (Overall mean not presented). | ↑ DNA mean tail length in welders | Limitations are related to outcome evaluation, such as the use of outdated methods no longer recommended, which could lead to inaccurate scoring. Also a lack of description/details on participant selection (e.g., concern for potential selection bias).; Comet assay conducted in all subjects, but micronucleus test conducted only in 58 welders and 53 controls, selected randomly from population (study reported ↑ MN in welders compared with controls and with increased duration of welding work). | Danadevi et al. (2004)
Exposed: Chrome-plating workers (n = 19); Referents 1: hospital workers (n = 18); Referents 2: university personnel (n = 20) | Assessment: Total Cr measured in urine, erythrocytes, and lymphocytes using graphite furnace atomic absorption.; Levels: Total Cr was higher in exposed workers compared with hospital workers (see Table 3; for example, postshift mean urine levels were 7.31 [SD = 4.33] in exposed vs. 0.12 [SD = 0.07] μg/g crt in referent).; Duration: Mean (SD) yr of exposure among chrome-plating workers = 6.3 (4.3). | In peripheral blood lymphocytes:; ↑ comet tail moment correlated with Cr lymphocyte concentrations; Null apoptotic nuclei | Did not exclude smokers (high prevalence) although did present results stratified by smoking (small numbers). Unclear whether exposure was to Cr(VI) specifically (possible with chrome plating workers but measured total Cr in urine). State that previous air monitoring for total chromium showed levels of 0.4 to 5.6 μg/m^3^, which is fairly low.; The comet assay is an insensitive method for measuring apoptosis. | Gambelunghe et al. (2003)
Exposed: chromium exposed workers (n = 10); Referents: nonexposed workers (n = 10) | Assessment: Urine and blood samples were taken from workers at the end of a work week.; Levels: Chromium concentrations in the factory ranged from 0.001 to 0.055 mg Cr(VI)/m^3^ (obtained from personal and area samplers). Mean chromium concentrations in urine (5.97 μg/g creatinine), whole blood (5.5 μg/L), plasma (2.8 μg/L), and lymphocytes (1.01 μg/10^10^ cells) of exposed workers were significantly higher than in nonexposed workers.; Duration: The mean duration of exposure was 15 yr. | No difference in DNA strand breaks (alkaline elution assay) between groups | Very small sample and low exposure levels, which probably limited power.; Study also reported no increased incidence in 8-OHdG. | Gao et al. (1994)
Exposed 1: male welders working in areas without collective protections (n = 27); Exposed 2: male welders working in locations with smoke extraction systems (n = 33); Referents: office workers with no history of occupational exposure to welding fumes or other physical/chemical agent in workplace (n = 30) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured total Cr in blood and urine.; Levels: Cr levels in blood and urine were higher among both groups of welders compared with controls (means 129 to 145, compared with 92 μg/L), and urinary chromium was higher among welders working without smoke extraction systems.; Duration: Welders exposed for 0.5–45 yr. | ↑ OTM_x_^2^ distribution (measure of DNA damage) in welders at the end of the work week compared with beginning; ↑ DNA strand breaks at end of work week in welders | Main limitations are lack of description (e.g., for participant selection, analysis), unknown contribution of Cr(VI) to Cr exposure, and known coexposures to other metals.; Study also reported ↑ frequency of chromosomal damage in welders. | Iarmarcovai et al. (2005)
Cross-sectional study, Brazil.; Exposed: n = 50 male chrome platers exposed to Cr(VI); Referent: n = 50 male unexposed controls | Assessment: Cr measured in whole blood and in urine.; Levels: Concentrations of Cr in both blood and urine were significantly higher in exposed compared with unexposed. Mean ± SD levels in blood for exposed and unexposed were 2.02 ± 0.20 and 1.73 ± 0.16 μg/L, respectively; levels in urine were 10.65 ± 5.26 and 4.05 ± 3.78 μg/g creatinine, respectively.; Duration: At least 1 yr of Cr(VI) exposure for exposed workers; Mean ± SD of 6.97 ± 7.35 yr duration | In buccal cells:; ↑ DNA damage measured by the comet assay in exposed workers | Study also reported no significant difference in MN between exposed and non-exposed group (p < 0.05) | Muller et al. (2020)
Exposed: welders (n = 93); Referents: general population controls with no history of occupational exposure to welding fumes; age and SES-matched to exposed group (n = 60) | Assessment: Exposure determined by occupation.; Levels: Not reported.; Duration: 5–15 yr. | ↑ DNA mean tail length in welders compared with controls; Study was not included due to a critically deficient rating in the exposure domain when evaluated in HAWCfor the micronucleus frequency endpoint. | Study also reported ↑ frequency of MN in welders compared with controls and in welders with increased duration of work. | Sellappa et al. (2010)
Exposed: male welders (n = 66); Referents: male individuals from the general population with no history of occupational exposure to welding fumes or other physical/chemical exposure in workplace; age and SES-matched to welders (n = 60) | Assessment: Exposure determined by occupation.; Levels: Not reported.; Duration: Duration of welding ranged from 5–20 yr. | ↑ DNA mean tail length in welders compared with controls, and in welders with increased duration of work | Study also reported ↑ frequency of MN in welders compared with controls and in welders with increased duration of work. | Sudha et al. (2011)
Exposed: individuals (n = 115; 29 females, 86 males) with exposure to sodium dichromate for at least 6 mo; Referents: healthy volunteers (n = 60; 15 females, 45 males) in the same city without chromate exposure history. | Assessment: Air-Cr concentration collected with point dust sampler and measured with electrothermal atomic absorption spectrometry. Personal air samples collected through full-shift (8h) sampling to calculate cumulative dose postshift blood samples collected; chromium measured with ICP-MS.; Levels: Mean (SD) chromium in blood of exposed workers = 12.45 (20.28) μg/L. ↑ accumulation of Cr in peripheral red blood cells in chromate-exposed workers.; Duration: Mean (SD) yr of employment among exposed group: 12.86 (6.02); range: 1–33. | ↑ urinary 8-hydroxy-2-deoxyguanosine, DNA strand breaks and global DNA hypomethylation in chromate-exposed workers | Urinary 8-hydroxy-2’-deoxyguanosine, DNA strand breaks and global DNA hypomethylation.; No adjustment for diet or other nonfolate supplements.; ↓ serum folate in chromate-exposed workers. | Wang et al. (2012)
Exposed: electroplating workers (n = 157); Referents: individuals without exposure to chromium or known physical/chemical genotoxic agents (n = 93) | Assessment: Air-Cr and blood Cr determined by graphite furnace atomic absorption spectrophotometer.; Levels: median (range) Cr in erythrocytes (μg/L) among exposed: 4.41 (0.93–14.98); among controls: 1.54 (0.14–4.58). Median (range) short-term concentrations of Cr in air: 0.060 (0.016–0.531) mg/m^3^.; Duration: Median (min–max) yr of exposure among exposed group: 5.3 (0.5–23). | ↑ 8-OHdG adducts among exposed compared with referents; ↑ Olive tail moment, tail length, & tail DNA% among exposed compared with referents | Limited adjustment for confounders (including diet).; Potential coexposures to other metals in the workplace. | Zhang et al. (2011)
Rat, Wistar | Intratracheal instillation, 1.3 and 2.5 mg/kg Na_2_Cr_2_O_7_, 24 h. | ↑ DNA strand breaks in peripheral lymphocytes | Fluorometric analysis of DNA unwinding (FADU) assay. | Gao et al. (1992)
DNA-protein crosslinks
Exposed 1: Full-time tannery workers, directly involved in chromium tanning or finishing process (n = 33); Exposed 2: Full-time manual metal arc stainless steel welders (n = 5); Referents: Control individuals with no known exposure to environmental or occupational carcinogens (n = 30) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in plasma and in urine (mid-shift for welders).; Levels: Urinary and plasma chromium levels were higher in both exposed groups compared with controls. For example, mean ± SD levels in plasma were 2.43 ± 2.11 in tanners, 1.55 ± 0.67 in welders, and 0.41 ± 0.11 μg/L.; Duration: Not reported. | ↑ DNA-protein crosslinks in tannery workers & welders compared with controls | Main limitation is small number of welders, lack of description for participant selection, analysis, and confounders.; Study also reported ↑MN in tannery workers & welders compared with controls. | Medeiros et al. (2003)
Exposed: residents living near Hudson County, New Jersey chromium-containing landfills and with urinary chromium ≥0.5 μg/L (n = 33); Referents: individuals living in noncontaminated areas (n = 49) | Assessment: No description of exposure assessment protocol.; Levels: Based on recruitment, exposed group had urinary chromium ≥0.5 μg/L.; Duration: Not reported. | ↑ DNA-protein crosslinks in exposed compared with controls, after adjustments for covariates | Control for the covariates (age, gender, race, smoking, weight) increases confidence in results.; Unclear whether chromium measures were also assessed in the control population and whether unexposed status was confirmed. | Taioli et al. (1995)
Exposed: male stainless steel welders working in open environment (n = 5); Referents: age-matched male control blood samples obtained from local blood center (n = 22) | Assessment: Based on occupation. Welders worked in stainless steel industry using acetylene flame method in open environment without protective masks over nose or mouth.; Levels: Not reported.; Duration: Not reported. | ↑ DNA-protein crosslinks in lymphocytes of welders; ↓ excess of glutathione over cysteine in welders | Comparisons of reduction rates and extent of DNA damage and DNA-protein adducts to levels of intracellular reductants glutathione and cysteine.; Small sample size limits confidence in results. | Quievryn et al. (2001)
Exposed: Chrome-platers from metallurgic plant (n = 14); Referents: residents of the same town, not living in vicinity of the factory and not known to be exposed to chromium or other metals (n = 12) and additional unexposed individuals living in nearby coastal town (n = 6) | Assessment: Personal breathing sampling pump with sampling flow of 21 min^−1^ for all workers over the course of one 8-h shift; collection using Millipore filters; analyzed with atomic absorption flame method for total chromium.; 11 workers also fitted with pumps with medium range flow (1.21 min^−1^); collection with 5-mm PVC filters; analyzed with visible absorption spectrophotometer for Cr(VI), with portion of each sample analyzed for total chromium by flame atomic absorption.; Blood samples collected post work shift; analyzed with flameless atomic absorption spectrometry.; Urine samples collected pre & post work shift; Levels: Ambient levels of total chromium in chrome-plating plant ranged from 0.009 to 0.327 mg/m^3^ (median = 0.041 mg/m^3^) as measured with Millipore filters and from 0.008 to 0.19 mg/m^3^ (median = 0.027 mg/m^3^) measured by Higitest filters. Cr(VI) levels in ambient air ranged from 0.0005 to 0.13 mg/m^3^ (median = 0.003 mg/m^3^).; Duration: Workers had been continually employed at metallurgic plant for 8-h work shifts for 1.5–15 yr (mean: 9.5 ± 4.0). | ↑ chromium in pre-& postshift urine, erythrocytes, and lymphocytes elevated in exposed compared with referents; No difference in DNA-protein crosslinks between exposed and referents; however, there were + associations between DNA protein crosslinks and chromium in erythrocytes at low and moderate exposures with saturation at higher exposure levels | Small sample size limits confidence.; No consideration of covariates.; Potential confounding by other occupational exposures. | Zhitkovich et al. (1996)
Exposed: railroad arc welders (n = 21); Referents: unexposed controls (office workers, supervisors, janitors, laboratory technicians) (n = 26) | Assessment: Chromium and nickel measured in blood of controls and welders with atomic absorption.; Levels: No difference in nickel levels between groups; small but not statistically significant difference in chromium between groups (numbers not provided).; Duration: Welders had been exposed full time to welding fumes for at least 6 mo, but not stainless-steel welding. | ↑ DNA-protein cross-links in welders compared with controls | Unclear how an effect detected was when there was no overall/meaningful difference in chromium or nickel between groups – could possibly be due to an unmeasured confounder.; The exposed group did not actually experience high levels of Cr exposure, which might have limited power to detect effects.; Small sample size limits confidence. | Costa et al. (1993)
Sister chromatid exchange
Exposed: Chromium plate workers (n = 15); Referents 1: age, gender, smoking-matched controls (n = 15); Referents 2: individuals of similar age from unpolluted rural region (n = 8) | Assessment: Blood samples and buccal mucosal cells taken from exposed group; exposure was estimated with personal air samplers and in urine samples.; Levels: Mean air concentration of total chromium was 0.0075 mg chromium/m^3^ in the low-exposure group and 0.0249 mg chromium/m^3^ in the high-exposure group (number of workers in each exposure group was not reported).; Mean concentrations of chromium in urine were 18.63 μg/L (low) and 104.22 μg/L (high); Duration: Duration of exposure ranged from 2 to >20 yr; mean duration of exposure was not reported. | No difference in SCE/cell between exposed and controls | Although exposed and unexposed workers were matched on age, sex, and smoking habit, the two unexposed (worker and rural) groups were combined, resulting in lower confidence in comparability of exposed and unexposed group comparisons. Inference is further limited by small sample size and lack of description.; Study also reported ↑ micronuclei in peripheral lymphocytes and buccal cells in workers compared with controls. | Benova et al. (2002)
Exposed: chromium electroplating workers (n = 7); Referents: age and sex-matched nonexposed office employees (n = 10) | Assessment: Air samples from the electroplating room were collected, along with stool and hair samples to determine exposure.; Levels: The mean chromium (total) air concentration (by random air collection) was 8.1 μg/mm^3^, the mean chromium concentration in stool samples was 8.5 μg/g stool, and the mean chromium concentration in hair was 35.68 μg/g. The valence of chromium that workers were exposed to was unspecified.; Duration: Mean employment period of 12.8 yr among exposed groups. | ↑ chromosomal aberrations and sister chromatid exchanges (SCE) in exposed group | Although controls were age and sex matched to exposed subjects and were stated to have similar socioeconomic status, the sample size is quite small and the analysis limited. Also unclear how well differentiated chromium exposure is by group—analyses of chromium in hair suggest delineation with controls, but no information on stool samples, which showed similarities between nickel and chromium workers.; Also reports coexposure to nickel. | Deng et al. (1988)
Exposed: male stainless steel welders (n = 23); Referents: men employed in office of printing company (n = 22) | Assessment: Urine sampling at end workday to evaluate chromium concentration.; Levels: Urinary chromium levels ranged from 0.20 to 1.55 μMole/L.; Duration: Welders had been employed in manual metal arc (MMA) welding for at least 4 yr; mean (SD) length of employment = 21 (10). Welders worked in poorly ventilated areas. | No differences in SCE between exposure groups | Although Cr(VI) exposure seems likely to occur among these welders, the analysis is limited by small sample size when stratifying by smoking (found to be related to the outcome).; Study also reported no differences in CA between exposure groups. | Husgafvel-Pursiainen et al. (1982)
Exposed: male stainless steel welders (survey 1 n = 17; survey 2 & 3 n = 44); Referents: male office workers (survey 1 n = 6; survey 2 n = 7; survey 3 n = 20) | Assessment: Classification based on occupation. Spot urine samples collected during workday; analyzed with direct flameless atomic absorption spectrometer.; Levels: Mean urinary Cr was 9.8 and 4.2 μg/L among exposed and referent group, respectively.; Duration: Stainless steel welders employed for 5–20 yr (mean 12.1). | No differences in sister chromatid exchanges (SCE) in exposed compared with controls | The main limitations are related to the outcome evaluation and to poorly described and reported data analysis and lack of consideration of potential confounders.; Study also reported ↑ chromosomal aberrations in exposed compared with controls. | Koshi et al. (1984)
Exposed 1: chromium exposed electroplating male workers (n = 14); Exposed 2: nickel-chromium exposed electroplating male workers (n = 34); Referents: male administrative workers free of exposure to heavy metals and solvents (n = 43) | Assessment: Urine and blood samples collected; analyzed with atomic absorption spectrophotometry.; Levels: Cr workers had the highest blood Cr (11.39 lg/L) and urine Cr concentrations (14.7 lg/g creatinine).; Duration: At least 6 mo of electroplating experience at the start of the study. Mean (SD) yr of work among chromium workers = 6.6 (5.8); among nickel-chromium workers = 3.7 (4.6). | ↑ sister chromatid exchanges and high frequency cells in Cr & Ni-Cr groups | Small sample size limits confidence.; Observed synergistic effect with smoking. | Lai et al. (1998)
Exposed: manual metal arc stainless steel welders (n = 24); Referents: matched controls (n = 24) | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured total Cr in air (welders only) and urine (all).; Levels: Mean urinary Cr was 47 and 1.5 μMol/mol creatinine among exposed and referent group, respectively. Mean air Cr level 81 μg/m^3^.; Duration: Welders were selected for their “long and intense” welding on stainless steel (mean work duration of 19 yr). | No difference in cytogenetic effects (i.e., chromosomal aberrations, sister chromatid exchanges, or micronuclei) between groups | Main limitations are related to outcome ascertainment and statistical analysis and to limited description of results. | Littorin et al. (1983)
Exposed: male chromium platers (n = 12); Referents: none | Assessment: Venous blood and urine sample were collected over a 5 yr period.; Levels: Urinary chromium concentrations ranged from 1.2 to 57.0 μg/g with a mean urinary chromium concentration of 17.9 μg/g creatinine.; Duration: Employment duration ranged from 6.6 to 25.1 yr, with mean employment duration of 15.5 yr. | No association between urinary Cr and sister chromatid exchanges | Small sample size and no control group used in study limits exposure comparisons and power for analysis; limited adjustment for confounders. | Nagaya et al. (1991)
Exposed: male chromium platers (n = 44); Referents: male controls unexposed to Cr or other harmful agents (n = 47) (further grouping by smoking within exposed and referents) | Assessment: Urinary collected during working hr; analyzed with direct flameless atomic absorption spectrophotometer.; Levels: Mean among all chromium platers = 0.25 μMol/L.; Duration: Duration of employment: 0.5–30.7 yr [mean (SD): 13.8 (8.7)]. | No association between urinary Cr and sister chromatid exchanges | Limited adjustment of confounders: considered stratification only by smoking status. | Nagaya et al. (1989)
Exposed: male chromium platers (n = 24); Referents: sex, age, smoking-matched office worker controls, unexposed to Cr (n = 24) | Assessment: Urine samples analyzed with direct flameless atomic absorption spectrophotometer.; Levels: The mean (SD) concentration of chromium in the urine was 13.1 (16.7) μg/L.; Duration: Duration of employment ranged from 0.5 to 30.5 yr with a mean employment of 11.6 yr. | No difference in SCEs between exposed and unexposed groups; no association between urinary Cr and sister chromatid exchanges among exposed | Authors suggest that null results could be due to low exposures.; Consideration of smoking but minimal other confounders. | Nagaya (1986)
Exposed: male welders (n = 39); Referents: unexposed men (n = 18) | Assessment: Chromium in urine samples (time of day unspecified) from workers analyzed with atomic absorption spectrometry.; Levels: Mean (SD) chromium among welders = 28.4 (19.8) μg/L.; Duration: Authors state that employees had been employed since 1983 (paper published in 1991); ~7–8 yr (?). | ↓ sister chromatid exchange frequency in welders compared with controls | Only considered age and smoking as potential covariates.; Authors note some concern with alkaline filter elution that might impact validity of results. | Popp et al. (1991)
Exposed: male chromium platers (n = 38); Referents: male sanitary workers unexposed to ionizing radiation for at least 5 yr & no mutagenic drugs(n = 35) | Assessment: Exposure to Cr(VI) inferred based on occupation. Exposed group was stratified based upon coexposure to nickel (“bright” plating, vs. “hard” plating). Also measured Cr in urine.; Levels: Urinary Cr levels were lowest in controls (mean ± SD = 1.9 ± 1.4 μg/g crt), intermediate in bright plating (6.1 ± 2.8 μg/g crt), and highest in hard plating groups (10.0 ± 7.5 μg/g crt), indicating adequate delineation between groups.; Duration: Mean (SD) yr of exposure: bright plating = 9 (11); hard plating = 7 (3). | Association between urinary Cr and sister chromatid exchanges | Main limitations are related to outcome ascertainment, small sample size for certain analyses, and lack of description (e.g., for participant selection and statistical analysis).; Study also reported ↑ chromosomal aberrations and sister chromatid exchanges in exposed groups. | Sarto et al. (1982)
Exposed: chromium platers (n = 12); Referents: controls (n = 10) | Assessment: Based on occupation.; Levels: Cr(VI) exposure levels and blood concentrations were not reported.; Duration: Exposure durations ranged from 0.5 to 18 yr (mean exposure duration was not reported). | ↑ sister chromatid exchanges in exposed group | Very small sample size; no consideration of confounders; no exposure information on participants.; Results supported by in vitro findings (human lymphocytes cultured & treated with Cr(VI) and Cr(III). | Stella et al. (1982)
Exposed: chromium workers (n = 35); Referents: age and gender-matched controls (n = 35) | Assessment: Based on occupation.; Levels: Not reported.; Duration: Exposure duration ranged from 2 to 14 yr with a mean (SD) of 6.5 (4.2) yr. | ↑ sister chromatid exchanges in exposed group; association with work duration; synergy with smoking; ↑ high frequency cells in exposed group; synergy with smoking | No quantitative assessment of exposure; exposure based on work only; limited sample size.; Only adjusted for smoking, no other confounding incorporated into Cr analysis. | Wu et al. (2000)
Exposed: chromium platers (n = 35); Referents: healthy subjects with no history of disease or previous exposure to chromium or other metals (n = 35) | Assessment: Personal exposure monitoring for 8 hr working shift (1.71/min) on only 10 individuals in the exposed group.; Blood and urine samples collected at end of shift and analyzed with atomic absorption spectrophotometry.; Levels: Individual time-weighted average range: 0.049–1.130 mg/m^3^.; Duration: The mean duration of employment was 6.5 yr. | ↑ sister chromatid exchange and percent high frequency cells in exposed group compared with controls | Personal air sampling only obtained for n = 10 individuals in the exposed group; SCE analysis conducted based on work group rather than measured exposure level.; Unable to draw conclusions about effect of genotype due to small sample size. | Wu et al. (2001)
Exposed: male welders (n = 39); Referents: matched controls not substantially exposed to carcinogens (n = 39) | Assessment: Venous blood samples analyzed with atomic absorption spectrometry.; Levels: Mean (SD) concentration of chromium in exposed group erythrocytes: 4.3 (7.0) μg/L.; Duration: Not reported. | ↑ sister chromatid exchange and DNA single strand breaks in exposed compared with controls | Only considered smoking status, no other covariates.; Possible confounding by coexposure to other toxic metals, such as nickel, which was also measured in this study. | Werfel et al. (1998)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

###### Oral route of exposure

###### Mutagenic MOA studies

Studies considered most relevant to a mutagenic MOA analysis for cancer of the GI tract are studies that measure gene mutation (prior to tumorigenesis), micronuclei induction, and chromosomal aberrations following oral exposures in experimental animals. This includes gavage exposures with the acknowledgment that this dosing regimen condenses the exposure time, inhibiting gastric reduction and potentially increasing Cr(VI) exposure. Human studies of occupationally exposed workers that tested GI tissues (i.e., buccal cells from the oral cavity) were also considered. Although these subjects were exposed via inhalation, this route of exposure is presumed to be relevant to tissues in the oral cavity given exposure when breathing and via mucociliary clearance.

No oral exposure studies in humans meeting these criteria were identified, but eight studies reporting occupational measures of mutagenic biomarkers in buccal cells were identified; these studies have already been summarized with the mutagenic MOA studies for inhalation exposures in the preceding section. Eighteen studies in animals exposed via drinking water, diet, or gavage were identified; some of the findings reported in these studies are visualized in Figures C-21 to C-24. These studies were evaluated in HAWC; the evaluations and the study findings are summarized in Tables 3-18 and 3-19 in Section 3.2.3.3 of the toxicological review.

Figure C-21 Overview of selected studies evaluating mutagenic markers in the gastrointestinal tract of mice following ad libitum drinking water exposure.

Full circle of a pie chart represents 2 years. Bar chart represents the maximum dose range or the dose where an effect is first observed (whichever is lower). Full or empty circles represent sample size per group (darkened if an effect was observed).

Figure C-22 Overview of the NTP (2007f) genetic toxicology (ad libitum drinking water exposure).

Full circle of a pie chart represents 2 years. Bar chart represents the maximum dose range or the dose where an effect is first observed (whichever is lower). Full or empty circles represent sample size per group (darkened or shaded if an effect was observed).

Figure C-23 Overview of selected studies evaluating mutagenic markers (but finding no effect) following ad libitum drinking water exposure (left) and oral gavage (right).

Full circle of a pie chart represents 2 years. Bar chart represents the maximum dose range. Empty circles represent sample size per group.

Figure C-24 Overview of the Thompson et al. (2015a) study evaluating mutagenic markers in rats (but finding no effect) following ad libitum drinking water exposure.

Full circle of a pie chart represents 2 years. Bar chart represents the maximum dose range. Empty circles represent sample size per group.

###### Supporting genotoxicity studies in gastrointestinal tract tissue

In addition to the studies measuring gene and chromosomal mutation identified above, mechanistic evidence of genotoxicity in GI tract tissues or in cells isolated from the GI tract were identified in the preliminary title and abstract screening. These studies were tagged as “mechanistic” and further screened and tagged as “GI tract” and “cancer” if they were studies in humans or animals conducted in GI tissues or cells that were relevant to carcinogenic processes. Seven genotoxicity studies of GI tissues in experimental animals and 10 studies in cells derived from GI tissues were identified; no human studies were identified. This evidence is summarized in Table C-50.

Table C-50 Supporting genotoxicity studies in gastrointestinal tract tissues and cells following Cr(VI) exposures

System | Exposure^a^ | Results | Reference
Mouse, B6C3F1, female; Oral, drinking water | 0, 0.1, 1.4, 4.9, 20.9, 59.3, and 181 mg/L Cr(VI); 0, 0.024, 0.32, 1.1, 4.6, 11.6, or 31.1 mg/kg-d Cr(VI); 7 d (n = 5) or 90 d (n = 10) | 7 and 90 d:; No increases in 8-OHdG adducts in any tissues | Thompson et al. (2011b)
Mouse, B6C3F1 & rat, F344, female; Oral, drinking water | 0 and 180 mg/L Cr(VI); 0 and 31.1 mg/kg-d Cr(VI); 13 wk | γH2AX elevated over background in duodenal villi but not crypts (foci not quantified); No aberrant foci indicative of transformation | Thompson et al. (2015a); Continued analysis of tissues from Thompson et al. (2011b)
Mouse, B6C3F1; Oral, drinking water | 0, 1.4, 21, and 180 mg/L Cr(VI); 0, 0.32, 4.6, and 31.1 mg/kg-d Cr(VI); 7 d | No effect on γH2AX in crypt enterocytes (no scoring methods described; no quantitative results presented); No effect on micronucleus induction in crypt enterocytes (low confidence; see Section 3.2.3.3) | Thompson et al. (2015b)
Mouse, SKH-1 hairless, female; Oral, drinking water | 0, 5, and 20 mg/L Cr(VI); 1.20 and 4.82 mg Cr(VI)/kg-d; 9 mo | No effect on DNA-protein crosslinks or oxidative 8-OHdG adducts in forestomach, glandular stomach, duodenal cells, lung or skin; No measure of cytotoxicity | De Flora et al. (2008)
Mouse, C57BL/6J; Oral, drinking water | 0, 0.019, 0.19, 1.9 mg/L Cr(VI); 150 d; 2 animals per dose group | In proximal and distal sections of GI tract:; Immunohistochemistry: 1.5-fold increase in γH2AX in distal sections; Histopathology: No villous atrophy/blunting or inflammation; slight enterocyte hypertrophy in PSI that grew in severity in DSI; and slight crypt hyperplasia; No effect on number of Ki67-positive cells | Sánchez-Martín et al. (2015)
Rat; Oral gavage | 530 mg/kg-d Cr(VI), 3 d; 106 mg/kg-d Cr(VI), 30 d; [underlined: Note]: The administered gavage potassium dichromate doses (1,500 mg/kg and 300 mg/kg) are higher than the LD_50_ for rats listed in MSDS (130 mg/kg) | Intestinal epithelial cells, 3 d exposure:; ↓ glucose-6-phosphate dehydrogenase, glutathione peroxidase, glutathione reductase, glutathione-S-transferase, superoxide dismutase and catalase; ↓ glutathione and total thiols; ↑ lipid peroxidation; Intestinal epithelial cells, 30 d exposure:; ↑ superoxide dismutase, glutathione peroxidase; Null glucose-6-phosphate dehydrogenase, glutathione reductase and catalase; ↓ glutathione-S-transferase | Sengupta et al. (1990)
Mouse, ddY, 4 per group; Oral gavage | 0 or 85.7 mg/kg Cr(VI); Single dose | p.o.: ↑ DNA damage (comet assay) in stomach, colon, and lung (also in brain, liver, kidney, bladder, but not in bone marrow) in cells collected 8 hr after treatment; Effects subsided at 24 hr in all dose groups; No clinical or microscopic signs of cytotoxicity | Sekihashi et al. (2001)
In vitro human primary and immortalized GI cells or gastric fluid
Human primary lymphocytes and gastric mucosal cells | 177 μM or 0.57 mM Cr(VI) | ↑ DNA damage (comet assay) (p < 0.001) | Błasiak et al. (1999), Trzeciak et al. (2000)
Pre- and post-meal gastric fluid samples from healthy volunteers (n = 8) | 0.021 mg/L Cr(VI) | ↓ mutagenicity of Cr(VI) (assessed via Ames reversion test) as a function of time in human gastric juice | De Flora et al. (2016)
Human gastric cancer SGC-7901 cells | 3.53 μM Cr(VI) | DNA damage (comet assay, γH2AX), oxidative stress, apoptosis and necrosis all increased when the Unconventional prefoldin RPB5 Interacting protein (URI) is knocked down | Luo et al. (2016)
Human primary gastric and nasal mucosa cells | 0.087–0.349 μMoles/mL Cr(VI) | ↑ DNA damage (comet assay) and cytotoxicity, equal sensitivity in human and rat primary gastric and nasal mucosal cells | Pool-Zobel et al. (1994)
Human lung epithelial A549 and colon HCT116 (MLH−/−) and DLD1 (MSH6−/−) cells | 1–20 μM K_2_CrO_4_, 3–12 h | ↑ survival, ↓ apoptosis in mismatch repair (MMR)-deficient cells; ↑ DNA DSBs (γH2AX) and apoptosis in MMR-proficient cells, dose-dependent; γH2AX foci occur in G2, but no G2 cell cycle arrest; No p53 induction in either cell type at subtoxic levels; MMR responsive to Cr-DNA adducts, not oxidative damage or crosslinks; In MMR+ cells, apoptosis induced by Cr-DNA adducts independently of p53 | Peterson-Roth et al. (2005); Zhitkovich et al. (2006)
Human colon HCT116 (MLH1−/−) and DLD1 (MSH6−/−), lung epithelial H460, and lung fibroblast IMR90 cell lines | 2–10 μMol/L K_2_CrO_4_, 3 hr | Ternary ascorbate-Cr-DNA adducts are substrate for error-prone mismatch repair (MMR) MSH2-MSH6 dimer, leading to ↑ DNA DSBs and ↑ apoptosis; Cells deficient in MMR have higher survival and lower DNA DSBs; Colon cells deficient in MMR have increased survival following Cr(VI) exposures, increasing probability of clonal selection of these cells | Reynolds et al. (2009)
Caco-2 human colorectal adenocarcinoma cells | 0.1, 0.3, 1, 3, 10, 30, 100 μM Cr(VI) | Increase in 8-OHdG at nontoxic and cytotoxic concentrations, increase in γH2AX only at cytotoxic concentrations (24 h) (decreased cell counts interpreted by authors as cytotoxicity may also be caused by DNA damage-induced growth arrest); No change in p53, annexin-V (apoptosis markers), LC3B (autophagy marker); Translocation of ATF6 to nucleus (ER stress response marker); Caco-2 cell line is unstable, making interpretation of results difficult | Thompson et al. (2012a)
Human SV40 transformed fibroblasts, Werner syndrome fibroblasts, primary human lung IMR90 fibroblasts, and human colon HCT116 MLH1−/− and MLH1+ cells | 0–30 μM K_2_CrO_4_, 3 h | ↑ nuclear relocalization of WRN in response to Cr(VI); ↓ cell survival, ↑ DNA DSBs and ↓ RAD51 foci in cells lacking WRN; ↓ DNA DSBs in cells lacking mismatch repair; Error-prone mismatch repair of Cr-DNA adducts generates DNA DSBs and repair of persistent DNA DSBs is dependent on WRN helicase | Zecevic et al. (2009)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

###### Supporting oral exposure genotoxicity studies

Besides the studies identified above that reported gene or chromosomal mutations or measured genotoxicity endpoints directly in GI tissues, a small set of in vivo experimental animal studies was identified that measured genotoxicity in tissues other than the GI tract following oral exposures to Cr(VI). These studies identified in the preliminary title and abstract screening as “mechanistic” were further screened and tagged as “oral exposure, “cancer,” and “genotoxicity” if they were in vivo oral exposure studies that measured genotoxicity endpoints. After removal of endpoints already considered (see above), five genotoxicity studies in experimental animals were identified; no human studies were identified. This evidence is summarized in Table C-51.

Table C-51 Supporting genotoxicity studies in animals exposed via the oral route to Cr(VI)

System | Exposure^a^ | Results | Comments | Reference
Rat, Fischer 344 | Oral-drinking water, 0, 0.35, 1.77, 7.07 mg Cr(VI)/L, 48 hr; Comparison to single gavage doses (20 mL/kg) at same concentrations | No increase in unscheduled DNA synthesis in hepatocytes collected from the rat livers and analyzed in the in vivo-in vitro hepatocyte DNA repair assay | No measure of cytotoxicity; RDS not determined | Mirsalis et al. (1996)
Rat, Sprague-Dawley | Oral-drinking water, 0, 10.6, 35.4, 106.1 mg/L Cr(VI); 0, 2.49, 7.57, 21.41 mg/kg-d Cr(VI); 4 wk | In plasma: no change in 8-OHdG levels | ↑ MDA at two high doses; ↑ GSH-Px; ↑ global DNA methylation at two high doses; No change in P16 methylation | Wang et al. (2015)
Mouse, ddY, 4 per group | Oral gavage, 0 or 85.7 mg/kg Cr(VI); Single dose; Also i.p.: 0 or 32.1 mg Cr(VI)/kg | p.o.: ↑ DNA damage (comet assay) in stomach, colon, liver, kidney, bladder, lung, and brain, but not in bone marrow in cells collected 8 hr after treatment; i.p.: ↑ DNA damage (comet assay) in stomach, colon, and bladder (but not in liver, kidney, lung, brain, or bone marrow) at 8 h | Effects subsided at 24 hr in all dose groups; No clinical or microscopic signs of cytotoxicity | Sekihashi et al. (2001)
Mouse, Swiss albino | Oral gavage, 0, 0.21, 0.42, 0.84, 1.68, 3.37, 6.7, 13.5, or 26.9 mg/kg Cr(VI); Single dose | ↑ DNA strand breaks (comet assay) in leukocytes at 24, 48, 72, and 96 hr and 1 and 2 wk posttreatment; Dose-response from 0.59–9.5 mg/kg. Peak response at 48 hr. No cytotoxicity detected (trypan blue). | | Dana Devi et al. (2001)
Mouse, Swiss albino | Oral gavage, 0, 8.8, 17.7, and 35.4 mg/kg Cr(VI); Single dose or 1×/d, 5 d | ↑ DNA damage (comet assay) in lymphocytes (statistically significant); increasing with dose | | Wang et al. (2006)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

###### Injection studies

Supporting evidence of the genotoxic effects of Cr(VI) is provided by studies investigating mechanisms of genotoxic effects by more direct routes of administration in vivo, e.g., intraperitoneal (i.p.) injection. Twenty-three studies, summarized in Table C-52, were identified that measured genotoxic endpoints in animals exposed to Cr(VI) via i.p. injection.

Table C-52 Genotoxicity studies in animals exposed to Cr(VI) via i.p. injection

System | Exposure^a^ | Results | Comments | Reference
Gene and chromosome mutation
Mouse, CD-1, male | i.p., 0, 20, 30, 40, and 50 mg/kg K_2_CrO_4_ (0, 5.4, 10.6, 14.1, or 17.7 mg Cr(VI)/kg), single dose | ↑ micronuclei in peripheral blood reticulocytes | | Awogi et al. (1992)
Mouse, BDF_1_, male; Mouse, Swiss albino, pregnant females | i.p., 0 or 17.7 mg/kg K_2_Cr_2_O_7_, 24 hr | ↑ micronuclei in bone marrow of males or dams (p < 0.001) and in peripheral blood and liver of fetuses (p < 0.001) | No effect on PCE/NCE ratios (no cytotoxicity); No effect on fetus body weights | De Flora et al. (2006)
Mouse, MS and ddY | i.p., 0, 12.5, 25, or 50 mg/kg K_2_CrO (0, 4.4, 8.8, or 17.7 mg Cr(VI)/kg), single dose | ↑ micronuclei in bone marrow at 17.7 mg Cr(VI)/kg; statistically significant trend | Cytotoxicity not reported | Hayashi et al. (1982)
Mouse, ddY, male | i.p., 40 mg/kg K_2_CrO_4_ (14.1 mg Cr(VI)/kg), single dose | In peripheral blood reticulocytes sampled at 0, 24, 48, and 72 hr and hepatocytes at 5 d post-partial hepatectomy:; ↑ micronucleus frequency | | Igarashi and Shimada (1997)
Mouse, Slc:ddY | i.p., 0, 30, 40, and 50 mg/kg K_2_CrO_4_ (0, 10.6, 14.1, or 17.7 mg Cr(VI)/kg), 1×/d, 2 d | ↑ micronucleus frequency in bone marrow cells; statistically significant dose-response | %PCEs decreased at two highest doses | Itoh and Shimada (1996)
Mouse, lacZ transgenic (Muta Mouse) | i.p., 40 mg/kg K_2_CrO_4_ (0 or 14.1 mg Cr(VI)/kg), 1×/d, 2 d, or single dose sampled on d 1 and d 7 | ↑ micronucleus frequency in peripheral blood reticulocytes; ↑ mutant frequency in liver at 1 d; ↑ mutant frequency in bone marrow at 7 d | 7 d postinjection is too long to detect MN in bone marrow; Cytotoxicity not reported | Itoh and Shimada (1997), Itoh and Shimada (1998)
Mouse, C57BL/6J/BOM, female, mated to T-stock male | i.p., 0, 10 or 20 mg/kg K_2_CrO_4_ (0, 2.7, or 5.4 mg Cr(VI)/kg) | + mouse spot test in offspring | Decline in number of surviving offspring with dose | Knudsen(1980)
Rat, white outbred, male | i.p., 0 or 14 mg K_2_Cr_2_O_7_/kg-body mass, single dose (4.9 mg/kg Cr(VI), 24 hr | Rodent dominant lethal test: dominant lethal mutation frequency of 0.665 by comparing the number of live fetuses in the Cr(VI) treatment group to the control group; Micronucleus test in bone marrow | Also exposed via gavage; was evaluated in HAWC for male repro and mutagenic outcomes | Marat et al. (2018)
Rat, Wistar | i.p. 21 mg K_2_Cr_2_O_7_/kg-body mass, single dose (4.9 mg/kg Cr(VI), 48 hr | ↑ chromosomal aberrations in the bone marrow but not in lymphocytes unless dose reached toxic levels | | Newton and Lilly (1986)
Mouse, CBA × C57BI/6J hybrid male | i.p., 0, 0.5, 1.0, 2.0, 10, or 20 mg/kg K_2_Cr_2_O_7_ (0, 0.18, 0.35, 0.70, 3.5, or 7.1 mg Cr(VI)/kg), single dose; i.p., 0, 1.0, or 2.0 mg/kg K_2_Cr_2_O_7_ (0, 0.35, 0.70 mg Cr(VI)/kg), 1×/d, 21 d | Rodent dominant lethal test; Single dose: Statistically significant decrease in embryo survival at 7.1 mg Cr(VI)/kg; Repeat dose: Statistically significant decrease in embryo survival at 0.7 mg Cr(VI)/kg | | Paschin et al. (1982)
Mouse, CBA × C57BI/6J hybrid male | i.p., 0, 1, 5, or 10 mg/kg K_2_Cr_2_O_7_ (0.35, 1.77, or 3.54 mg Cr(VI)/kg), single dose | ↑ micronucleus frequency in bone marrow at 24, 48, or 72 h; peak at 48 h | No measure of cytotoxicity | Paschin et al. (1982)
Mouse, BALB/c, C57BL/6, and DBA/2 | i.p., K_2_CrO_4_ | ↑ micronucleus frequency in PCEs in all mouse strains | | Sato et al. (1990)
Mouse, MS/Ae and CD-1, male | i.p., 0, 10, 20, 40, or 80 mg/kg K_2_CrO_4_ (0, 3.5, 7.1, 14.1, or 28.3 mg Cr(VI)/kg), single dose | ↑ micronuclei in bone marrow cells, dose-response | %PCEs decreased at highest dose | Shindo et al. (1989)
Mouse, ddY, CD-1, BDF1, and ms, male | i.p., 0, 15, 30, or 60 mg/kg K_2_CrO_4_, single dose, 24 hr | ↑ micronucleus frequency in PCEs in all mouse strains | | The Collaborative Study Group for the Micronucleus Test (1988) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=1234810)
Mouse, NMRI | i.p., 0, 12.12, 24.25, or 48.5 mg/kg K_2_CrO_4_ (0, 3.2, 6.49, or 13.0 mg Cr(VI)/kg), 2 doses 24 hr apart | ↑ micronuclei in bone marrow at 13 mg Cr(VI)/kg; statistically significant trend | Cytotoxicity not reported | Wild (1978)
Mouse, B6C3F1, male, 8–10/group | i.p., 0, 0.51, 5.1, and 51.0 μg Na_2_CrO_4_/d, 4 wk; (5.5 × 10^−5^, 0.055, 0.55 mg/kg Cr(VI)) | No significant increase in micronucleated erythrocytes (PCEs or NCEs) per 1,000 cells analyzed from peripheral blood collected at the end of the treatment period. | | Witt et al. (2000)
Mouse, BALB/c | i.p., 0 or 400 μMol K_2_Cr_2_O_7_ (20.8 mg Cr(VI)/kg), single dose | ↑ micronucleus frequency in bone marrow cells (p < 0.001); Significantly decreased %PCEs (PCE/NCE ratio = 0.64 ± 0.14) (p < 0.01) | In liver:; ↑ lipid peroxidation (p < 0.05); ↑ heme oxygenase (p < 0.001); ↓ GSH-peroxidase activity (p < 0.1); slight but nonsignificant reduction in GSH levels | Wroñska-Nofer et al. (1999)
DNA damage
Mouse, BDF1, female | i.p., 25mg/kg Na_2_Cr_2_O_7_ – acute; 12.5mg/kg – subchronic, single injection for acute (1–14 d) or every 4 wk for 128 d | ↑ changes in ploidy in acute group | N ranged from 3 to 5 per group. All regions of liver | Garrison et al. (1990)
Rat, Sprague-Dawley, male | i.p., 0, 2.5, 5.0, 7.5, and 10 mg/kg-d K_2_Cr_2_O_7_, 5 d | In peripheral blood lymphocytes: ↑ DNA damage (comet assay) | In liver: ↑ ROS, MDA, SOD, CAT activity | Patlolla et al. (2009b)
Mouse | i.p., K_2_CrO_4_ | DNA damage (comet assay) in liver, lung, kidney, spleen, and bone marrow | | Sasaki et al. (1997)
Rat, Sprague-Dawley, male | i.p., 20 or 50 mg/kg-d | 1 h: DNA-DNA and DNA-protein crosslinks in liver, lung and kidney; ↑ DNA strand breaks in liver 36–40 hr: DNA-protein crosslinks in lung and kidney | | Tsapakos et al. (1981), Tsapakos et al. (1983)
Mouse, albino male | i.p., 0 or 20 mg Cr(VI)/kg, single dose | DNA damage (comet assay), 15 min post-injection (all back to control levels at 3 hr):; ↑ liver, kidney; No increases in spleen, lung, brain | Same pattern as Cr(V) complexes; Cytotoxicity not reported; DNA damage reduced with deferoxamine | Ueno et al. (2001)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

#### In vitro studies

##### Human cells or cell lines

In vitro investigations of the mechanisms of genotoxicity induced by Cr(VI) can provide support to observations in vivo. Table C-53 summarizes in vitro genotoxicity findings in human primary cells or cell lines. In general, if a study was conducted only in cells derived from a specific tissue (e.g., lung, GI tissues, liver), the genotoxicity evidence may be summarized in those sections and not repeated here.

Table C-53 In vitro genotoxicity studies in human cells

System | Exposure^a^ | Results | Comments | Reference
Gene and chromosome mutation
WIL2-NS human B lymphoblastoid cells | 0, 0.01, 0.10, 1.00, 10, 100, and 1000 μM K_2_Cr_2_O_7_, 48 h | ↑ micronuclei, all concentrations (p < 0.001); ↑ necrotic cells ≥100 μM; ↓ nuclear division index | Folate deficiency increased DNA damage | Alimba et al. (2016)
Primary human lymphocytes from four donors | 0, 0.001, 0.01, 0.1, and 0.25 μg/mL K_2_Cr_2_O_7_, 48 h (0, 0.35, 3.54, 35.4, and 88.4 ng/mL Cr(VI)) | ↑ chromosomal aberrations, all concentrations (p < 0.05); ↑ micronuclei, all concentrations (p < 0.05); ↓ mitotic index with dose; cytotoxic dose (50% decrease) estimated to be 0.15 μg/mL | Significant increases in chromosomal mutations occurring at noncytotoxic concentrations | Botta et al. (1996)
TK6 human lymphoblastoid cells | 5 μM K_2_Cr_2_O_7_, 5 hr | “Hotspot” mutations at the hprt gene (6-thioguanine resistant):; C:G→A:T transversion, bp 243 (4.5%); A:T→T:A transversion, bp 247 (2%); G:C→A:T transition, bp 289 (2.5%); C:G→T:A transition, bp 312 (4%) | Hprt bp 243 is hotspot for H_2_O_2_ (G:C→C:G transversion) and BaP; Hprt bp 247 is hotspot for X-rays (A:T bp deletion); Overall, little overlap between Cr(VI) mutation spectra and that of oxidative DNA damaging agents | Chen and Thilly (1994a); (1994b)
HeLa cells | 1, 10, and 100 μM Na_2_Cr_2_O_7_; 1, 2.5, 8, 24, or 48 hr | Mutation spectra: Single-base substitutions at G/C predominant; More transversions and fewer transitions compared with spontaneous | Intracellular Cr(III) inhibits DNA synthesis and replication fidelity by inhibiting DNA synthesome polymerases α, δ, and ε | Dai et al. (2009)
Human dermal fibroblasts | 1–6 or 200 μM Na_2_CrO_4_, 6 hr | ↑ DNA DSBs (neutral comet assay; γH2AX foci) only in PCNA-positive cells that were ATM+/+; Low cytotoxicity and ROS generation detected previously | Cr(VI) exposure generates S-phase dependent DNA DSBs that activate ATM kinase | Ha et al. (2004)
Human bronchial fibroblasts (WTHBF-6 cells) | 1 μM Na_2_CrO_4_, 24, 48, or 72 hr | ↑ Chromosomal aberrations that decreased over time | | Holmes et al. (2006b)
HeLa and human lung bronchial epithelial cells | 0.25 μM Na_2_CrO_4_, 30 d, or 10 μM, 16 or 48 hr | ↑ chromosomal aberrations with acute or chronic exposures | Chromosomal instability caused in part by suppressed activation of BubR1 and expression of Emi1, causing activation of APC/C, following nocodazole-induced mitotic arrest activation | Hu et al. (2011)
Human fibroblasts | 0.1–1 μM K_2_Cr_2_O_7_, K_2_CrO_4_, 48 hr | ↑ Chromosomal aberrations and SCEs | | Macrae et al. (1979)
Primary human bronchial fibroblasts (PHBFs) | 1, 2.5, 5 and 10 μM Na_2_CrO_4_, 24hr | ↑ Chromosomal aberrations (1 and 2.5 μM induced 19 and 43 aberrations per 100 metaphases) | Relative cell survival 74, 57, 13 and 0% after exposure to 1, 2.5, 5 and 10 μM; Complete cell cycle arrest ≥5 μM | Wise JP et al. (2002)
DNA damage
TK6 human lymphoblastoid cells | 0.2–1 mM CrCl_3_ and Na_2_CrO_4_ | ↑ DNA strand breaks (comet assay); associated with oxidized base damage as measured by FPG and Endolll addition | Cr(VI) delayed IR-induced DNA damage repair | El-Yamani et al. (2011)
Human fibroblast strains CRL 1187, XP12BE (CRL1223) and XP25RO (CRL 1261) | 0, 2, 5, 50 μM K_2_CrO_4_, 4 hr | ↑ DNA single-strand breaks induced in cells both deficient and proficient in excision repair | Other repair mechanisms involved in repair of DNA SSBs | Fornace (1982)
H460 human lung epithelial cells, IMR90 normal human lung fibroblasts, and normal mouse embryonic fibroblasts | 0, 5, 10, 15, and 20 μM K_2_CrO_4_ | DNA damage response to Cr(VI)-induced DNA doublestrand breaks (γH2AX foci) dependent on ATR kinase and not ATM in ascorbate-restored cells; DNA DSBs only formed in euchromatin | Involvement of ATR and DSBs forming in actively transcribed regions increases the probability that Cr(VI) can generate carcinogenic mutations | Deloughery et al. (2015)
Human U2OS osteosarcoma cells, Werner syndrome skin fibroblasts (AG03141), WI-38 fetal lung fibroblasts, telomerase-immortalized cell lines (hTERT GM01604, (hTERT AMIE15010, AG03141, hTERT BJ skin fibroblasts) | 0–4 μM Cr(VI), 6–48 hr | ↑ γH2AX foci in S-phase; ↑ WRN colocalization at γH2AX foci; ↑ telomere defects exacerbated by lack of telomerase; Lack of WRN slowed Cr(VI)-induced DNA DSB repair | Cr(VI) induces DNA DSBs and stalled replication forks; WRN helicase plays a role in the cellular recovery from Cr(VI)-induced replicative stress | Liu et al. (2009, 2010a)
Wild-type and pol zeta mutated D2781N and L2618M human B-cell leukemia cell line | Na_2_Cr_2_O_7_ and KBrO_3_ | Increased sensitivity to DNA damage (micronuclei, SCE) in cells with weaker variants of DNA polymerase zeta | Increased susceptibility to Cr(VI)-induced mutations in variants of DNA replication enzymes | Suzuki et al. (2018)
Human TK6 lymphoblastoid, HeLa cervical carcinoma epithelial, and 293T kidney epithelial cells | 1–2000 μg/L K_2_CrO_4_, 10 min–14 d | Cytotoxicity ≥ 373 μg K_2_CrO_4_/L (=100 μg Cr/L) with survival rate of 50%, 17%, and 10% for HeLa cells, 293T and TK6 cells, respectively; Trace amounts (≥9.8 μg/L) of Cr(VI) initiate DNA damage response and genotoxicity that increases with time and dose | Primary Cr(VI)-induced DNA damage response pathways are error-free HR and error-prone TLS pathways | Tian et al. (2016)
Human SV40 transformed fibroblasts, Werner syndrome fibroblasts, primary human lung IMR90 fibroblasts, and human colon HCT116 MLH1−/− and MLH1+ cells | 0–30 μM K_2_CrO_4_, 3 hr | ↑ nuclear relocalization of WRN in response to Cr(VI); ↓ cell survival, ↑ DNA DSBs and ↓ RAD51 foci in cells lacking WRN; ↓ DNA DSBs in cells lacking mismatch repair | Error-prone mismatch repair of Cr-DNA adducts generates DNA DSBs and repair of persistent DNA DSBs is dependent on WRN helicase | Zecevic et al. (2009)
GM03714A, GM0131B, and GM0922B human lymphoblastic cell lines | K_2_CrO_4_ and ^51^CrO_4_^2−^ 0, 20, 50, 100, 150, and 200 μM, 3, 6, or 12 hr | Differences in cytotoxicity and DNA damage in response to Cr(VI) due to differences in rate of uptake of Cr(VI) among 3 individual cell lines | | Zhang et al. (2002)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

##### Non-human mammalian cells or cell lines

Many genotoxicity tests using in vitro (non-human) mammalian primary cells or cell lines have been conducted over several decades; Table C-54 is not a comprehensive compilation but represents the general types of tests in the evidence base, as well as the results, which are uniformly positive. A number of reports were identified that used Cr(VI) compounds as a positive control for newly developed genotoxicity assays and have not been included here.

Table C-54 In vitro genotoxicity studies of Cr(VI) in mammalian cell systems

Endpoint | Chemical form | Test system | Results^a^ | | Reference
Endpoint | Chemical form | Test system | Without activation | With activation | Reference
Forward mutations at TK locus | CaCrO_4_ | Mouse lymphoma cells (L5178Y tk+/tk−) | + | + | Mcgregor et al. (1987)
Forward mutations at TK locus | CaCrO_4_ | Mouse lymphoma cells (L5178Y tk+) | + | + | Mitchell et al. (1988)
Forward mutations at TK locus | CaCrO_4_ | Mouse lymphoma cells (L5178Y tk+) | + | + | Myhr and Caspary (1988)
Forward mutations at TK locus | CaCrO_4_ | Mouse lymphoma cells (L5178Y tk+) | + | + | Oberly et al. (1982)
Forward mutations at HGPRT locus | K_2_Cr_2_O_7_ | Chinese hamster ovary cells (AT3-2) and Chinese hamster cells (V79) | + | ND | Paschin et al. (1983)
Forward mutations at HGPRT locus | K_2_Cr_2_O_7_ | Chinese hamster cells (V79) | + | ND | Bianchi et al. (1983)
Chromosomal aberrations | CaCrO_4_, Na_2_CrO_4_, Na_2_Cr_2_O_7_, CrO_3_, K_2_CrO_4_, K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Levis and Majone (1979)
Chromosomal aberrations | K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Seoane and Dulout (1999)
Chromosomal aberrations | Na_2_Cr_2_O_7_, K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Majone and Levis (1979)
Chromosomal aberrations | CaCrO_4_, CrO_3_, K_2_CrO_4_ | Chinese hamster lung DON cells | + | ND | Koshi and Iwasaki (1983); Koshi (1979)
Chromosomal aberrations | CaCrO_4_ | Chinese hamster ovary cells (C3H10T1/2) | + | ND | Sen et al. (1987)
Chromosomal aberrations | CrO_3_, Na_2_Cr_2_O_7_, K_2_CrO_4_, K_2_Cr_2_O_7_ | BHK and Chinese hamster ovary cells | + | ND | Bianchi et al. (1980)
Chromosomal aberrations | CrO_3_, K_2_CrO_4_, K_2_Cr_2_O_7_ | Mouse mammary FM3A carcinoma cells | + | ND | Umeda and Nishimura (1979)
Chromosomal aberrations | K_2_CrO_4_, K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Macrae et al. (1979)
Chromosomal aberrations | Na_2_CrO_4_ | Chinese hamster ovary cells | + | ND | Blankenship et al. (1997)
Chromosomal aberrations | Na_2_CrO_4_ | Chinese hamster ovary cells (AA8 (parental), EM9 (XRCC1 mutant), and H9T3 | + | ND | Grlickova-Duzevik et al. (2006)
DNA fragmentation | K_2_CrO_4_ | Mouse L1210 leukemia cells | + | ND | Fornace et al. (1981)
DNA fragmentation | Na_2_CrO_4_ | Chinese hamster ovary cells | + | ND | Blankenship et al. (1997)
DNA strand breaks | K_2_Cr_2_O_7_ | Vero kidney fibroblasts, Pam 212 keratinocytes | + | ND | Flores and Pérez (1999)
DNA strand breaks | Na_2_Cr_2_O_7_ | Rat hepatocytes | + | ND | Gao et al. (1993a)
DNA strand breaks | Na_2_Cr_2_O_7_ | Rat primary lymphocytes | + | ND | Elia et al. (1994)
DNA strand breaks | K_2_Cr_2_O_7_ | Chinese hamster cells (V79) | + | ND | Bianchi et al. (1983)
DNA-protein crosslinks | K_2_CrO_4_ | Chinese hamster cells (V79-UL) | + | ND | Merk et al. (2000)
DNA-protein crosslinks | K_2_CrO_4_ | Mouse L1210 leukemia cells | + | ND | Fornace et al. (1981)
Unscheduled DNA synthesis | Na_2_Cr_2_O_7_ | Rat hepatocytes | + (T) | ND | Gao et al. (1993a)
DNA synthesis inhibition | K_2_Cr_2_O_7_ | Mouse L cells | + | ND | Nishio and Uyeki (1985)
Sister chromatid exchange | CaCrO_4_, CrO_3_, K_2_CrO_4_ | Chinese hamster lung DON cells | + | ND | Koshi and Iwasaki (1983); Koshi (1979)
Sister chromatid exchange | CaCrO_4_, CrO_3_, K_2_CrO_4_, K_2_Cr_2_O_7_, Na_2_CrO_4_, Na_2_Cr_2_O_7_, | Chinese hamster ovary cells | + | ND | Levis and Majone (1979)
Sister chromatid exchange | K_2_CrO_4_, K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Macrae et al. (1979)
Sister chromatid exchange | CrO_3_, K_2_CrO_4_, K_2_Cr_2_O_7_ | Chinese hamster cells DON | + | ND | Ohno et al. (1982)
Sister chromatid exchange | CrO_3_, Na_2_CrO_4_, Na_2_Cr_2_O_7_, K_2_CrO_4_, K_2_Cr_2_O_7_ | BHK and Chinese hamster ovary cells | + | ND | Bianchi et al. (1980)
Sister chromatid exchange | K_2_Cr_2_O_7_ | Chinese hamster ovary cells (V79) | + | ND | Bianchi et al. (1983)
Sister chromatid exchange | Na_2_Cr_2_O_7_, K_2_Cr_2_O_7_ | Chinese hamster ovary cells | + | ND | Majone and Levis (1979)
Sister chromatid exchange | K_2_Cr_2_O_7_ | Mouse blastocysts | + | ND | Iijima et al. (1983)

a + = positive, ± = equivocal or weakly positive, − = negative, (T) = toxicity, ND = no data

##### Non-mammalian test systems

The Ames assay is a standard genotoxicity test usually performed in customized strains of S. typhimurium or E. coli that are highly sensitive and specific for detecting mutagens (Williams et al., 2019). Table C-55 is not a comprehensive list but summarizes results from a representative selection of Ames tests and other genotoxicity tests for Cr(VI) conducted in bacterial or yeast systems.

Table C-55 In vitro mutation studies of Cr(VI) in bacterial and yeast systems

Endpoint | Chemical form | Test system | Results^a^ | | Reference
Endpoint | Chemical form | Test system | Without activation | With activation | Reference
Bacterial mutation assays
Reverse mutation | (NH_4_)_2_CrO_4_; CaCrO_4_; CrO_3_; K_2_CrO_4_ | S. typhimurium TA97, TA1538, TA98, TA100 | + | NS | De Flora et al. (1984)
Reverse mutation | (NH_4_)_2_CrO_4_; CaCrO_4_; CrO_3_; K_2_CrO_4_ | S. typhimurium TA1537 | ± | NS | De Flora et al. (1984)
Reverse mutation | (NH_4_)_2_CrO_4_; CaCrO_4_; CrO_3_; K_2_CrO_4_; Na_2_Cr_2_O_7_ | S. typhimurium TA1535 | − | − | De Flora et al. (1984), De Flora (1981)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA100 | + | − | De Flora (1979)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA97 | + | NS | De Flora et al. (1984)
Reverse mutation | Na_2_Cr_2_O_7_; (NH_4_)_2_CrO_4_; CaCrO_4_; CrO_3_; K_2_CrO_4_ | S. typhimurium TA1537, TA1538, TA98, TA100 | ± | NS | De Flora et al. (1984), De Flora (1981)
Reverse mutation | K_2_CrO_4_ | S. typhimurium TA98, TA100, TA1537 | + | ND | Arlauskas et al. (1985)
Reverse mutation | K_2_CrO_4_ | S. typhimurium TA100 | + | ND | Arlauskas et al. (1985)
Reverse mutation | K_2_CrO_4_ | S. typhimurium TA1535, TA1538 | − | ND | Arlauskas et al. (1985)
Reverse mutations | Na_2_Cr_2_O_7_ | S. typhimurium TA102 | + | + | Bennicelli et al. (1983)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA97, TA1978, TA100, TA102, TA92 | + | ND | Bennicelli et al. (1983)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA1535, TA1537, TA1538 | − | ND | Bennicelli et al. (1983)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA98 TA100, TA1535, TA1538 | + | + | Bianchi et al. (1983)
Reverse mutation | CaCrO_4_ | S. typhimurium TA97, TA98, TA100 | − | − | Brams et al. (1987)
Reverse mutation | CaCrO_4_ | S. typhimurium TA98 | − | ± | Dunkel et al. (1984)
Reverse mutation | CaCrO_4_ | S. typhimurium TA100, TA1535, TA1537, TA1538 | − | − | Dunkel et al. (1984)
Reverse mutation | CrO_3_, (NH_4_)_2_CrO_4_; K_2_Cr_2_O_7_; Na_2_Cr_2_O_7_ | S. typhimurium TA1978 (rec+), TA1538 (rec −) | + | ND | Gentile et al. (1981)
Reverse mutation | CrO_3_; Na_2_Cr_2_O_7_ | S. typhimurium TA102, TA2638 | + | ND | Watanabe et al. (1998)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA97, TA98, TA100, TA1535, TA1537 | + | + | Zeiger et al. (1992)
Reverse mutation | K_2_CrO_4_; K_2_Cr_2_O_7_ | S. typhimurium TA102 | + | ND | Marzin and Phi (1985)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA100 | + | + | Venier et al. (1982)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA98 | ± | − | Venier et al. (1982)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA1538 | − | − | Venier et al. (1982)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA102, TA2638a | + | − | Rydén et al. (2000)
Reverse mutation | Na_2_Cr_2_O_7_ | S. typhimurium TA100, TA98 | + | + | NTP (2007f)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA1535 pSK1002 | + | + | Yamamoto et al. (2002)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA100, TA1025, TA98 | + | ND | Le Curieux et al. (1993)
Reverse mutation | CaCrO_4_ | S. typhimurium TA98, TA1537, TA100, TA1535 | + | ND | Haworth et al. (1983)
Reverse mutation | K_2_CrO_4_ | S. typhimurium TA1537 | + | ND | LaVelle (1986)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA97a, TA98, TA100, TA102 | + | + | Tagliari et al. (2004a)
Reverse mutation | K_2_Cr_2_O_7_ | S. typhimurium TA100, TA1537, TA1538, TA1535 | − | ND | Kanematsu et al. (1980)
Reverse mutation | CaCrO_4_; CrO_3_; K_2_CrO_4_; Na_2_Cr_2_O_7_ | S. typhimurium TA1537, TA98, TA100 | + | + | Petrilli and De Flora (1977)
Reverse mutation | CaCrO_4_; CrO_3_; K_2_CrO_4_; Na_2_Cr_2_O_7_ | S. typhimurium TA1535 | − | − | Petrilli and De Flora (1977)
Reverse mutation | CaCrO_4_ | E. coli WP2 uvrA | − | ± | Dunkel et al. (1984)
Reverse mutation | K_2_CrO_4_ | E. coli WP2 uvrA pKm 101 | + | ND | Arlauskas et al. (1985)
Reverse mutation | K_2_Cr_2_O_7_ | E. coli WP2uvrA | + | ND | Venier et al. (1987)
Reverse mutation | K_2_CrO_4_ | E. coli 343/358, /415, /435, /477 | + | ND | LaVelle (1986)
Reverse mutation | CrO_3_; Na_2_Cr_2_O_7_ | E. coli, WP2/pKM101, WP2 uvrA/pKM101 | + | ND | Watanabe et al. (1998)
Reverse mutation | K_2_CrO_4_; K_2_Cr_2_O_7_ | E. coli Wp2 hcr− try−, B/rWP2 | + (Wp2 hcr) | ND | Kanematsu et al. (1980)
Reverse mutation | K_2_CrO_4_; Na_2_CrO_4_ | E. coli Wp2(try−) | + | ND | Venitt and Levy (1974)
Reverse mutation | K_2_CrO_4_; K_2_Cr_2_O_7_ | E. coli WP2uvrA, CM571 | + | ND | Seo and Lee (1993)
Reverse mutation | K_2_Cr_2_O_7_ | E. coli WP2, WP2uvrA, CM571 | + | ND | Nishioka (1975)
Reverse mutation | Na_2_Cr_2_O_7_ | E. coli, WP2 uvrA/pKM101 | + | + | NTP (2007f)
DNA damage indicator tests in bacterial systems
Subtilis rec-assay | K_2_CrO_4_; K_2_Cr_2_O_7_ | B. subtilis | + | ND | Nakamuro et al. (1978)
Subtilis rec-assay | (NH_4_)_2_CrO_4_; CrO_3_ Na_2_Cr_2_O_7_; K_2_Cr_2_O_7_ | B. subtilis | + | ND | Gentile et al. (1981)
Subtilis rec-assay | K_2_CrO_4_; K_2_Cr_2_O_7_ | B. subtilis H17 | + | ND | Nishioka (1975)
Subtilis rec-assay | K_2_Cr_2_O_7_ | B. subtilis NIG45, NIG17 | + | ND | Matsui (1980)
SOS Chromotest | K_2_CrO_4_; K_2_Cr_2_O_7_ | E. coli PQ37, PQ35 | + | − | Olivier and Marzin (1987)
SOS Chromotest | CrO_3_, K_2_CrO_4_, K_2_Cr_2_O_7_ | E. coli AB1157, GC2375, UA4202, PQ30 | + | ND | Llagostera et al. (1986)
SOS Chromotest | K_2_Cr_2_O_7_ | E. coli PQ37 | + | ND | Le Curieux et al. (1993)
umu Chromotest | K_2_Cr_2_O_7_ | S. typhimurium TA1535 | ± | − | Nakamura et al. (1987)
DNA polymerase arrest assay | Na_2_Cr_2_O_7_ | PSV2neo-based plasmid DNA | − | + | Bridgewater et al. (1994); Bridgewater et al. (1998)
Genotoxicity assays in yeast systems
Reverse mutation, gene conversion | K_2_Cr_2_O_7_ | S. cerevisiae D7 | + | ND | Kharab and Singh (1985)
Forward mutation | K_2_Cr_2_O_7_ | Schizosaccharomyces pombe 972, h− | ± | ND | Bonatti et al. (1976)
Mitotic crossing-over, mitotic gene conversion | CrO_3_ | S. cerevisiae D7 | + | ND | Fukunaga et al. (1982)
Mitotic gene conversion, reverse mutation | K_2_Cr_2_O_7_ | S. cerevisiae D7 | + | ND | Singh (1983)
Mitotic gene conversion, reverse mutation | Na_2_CrO_4_ | S. cerevisiae D7 | + | ND | Bronzetti and Galli (1989)
Mitotic gene conversion, reverse mutation | CrO_3_; K_2_Cr_2_O_7_ | S. cerevisiae D7 | + | ND | Vashishat and Vasudeva (1987)
Induction of disomic and diploid spores | K_2_Cr_2_O_7_ | S. cerevisiae D1S13 | + | ND | Sora et al. (1986)

a + = positive, ± = equivocal or weakly positive, − = negative, ND = no data; NS = not specified.

### C.3.2.3 Alters DNA repair or causes genomic instability (KC#3)

Mechanistic studies relevant to detecting Cr(VI)-induced suppression of DNA repair processes (except for those caused by Cr(VI)-induced epigenetic modifications) or genomic instability resulting from Cr(VI) exposure have been summarized in Table C-56.

Table C-56 Mechanistic studies relevant to altered DNA repair or genomic instability induced by Cr(VI) exposure

Study overview | Exposure^a^ | Results | Comments | Reference
Effects on DNA repair
Exposed: chromate workers (n = 87); Referents: employees with no direct contact with chromium products (e.g., managers, officers, support crew) (n = 30); Exclusions: cancer, cardiovascular disease, kidney disease, pulmonary disease | Workers exposed to chromate by inhalation for ~5.0 yr (IQR: 3.0–10.0 yr); Postshift fasting blood samples collected; measurement with ICP-MS. Mean (SD) blood Cr in exposed group: 14.5 (33) ng/mL | ELISA of DNA repair-related genes POLBeta, ASCC3, BRCC3, and XRCC2; XRCC2 and BRCC3 protein levels were statistically associated with miR-3940-5p levels | Main limitations are related to lack of description (e.g., for participant selection) | Li et al. (2014b)
Exposed: females working in the chromium industry; subgroups based on years of contact with chromium (1–2; 3–5; 7–10; 15+) (n = 66); Referents: females with no contact with the chromium industry (n = 15) | Exposure based on years working in the chromium industry (1–2; 3–5; 7–10; 15+) yr | ↓ DNA repair synthesis in lymphocytes in exposed group; nonlinear relationship with duration of contact with chromium | Limited sample size within each exposed group when analyzed by duration (1–2 yr: n = 13; 3–5 yr: n = 15; 7–10 yr: n = 21; 15+ yr: n = 17) | Rudnykh and Zasukhina (1985)
hTERT immortalized clonal cell line derived from human bronchial fibroblasts (WTHBF-6) | 0.1–0.3 μg/cm^2^ zinc chromate, 24, 72, and 120 hr | After 120 hr, but not 24 hr, Cr(VI) induced dose-dependent decreases in nuclear Rad51, inhibition of the nuclear import of Rad51C and BRCA2, inhibition of Rad51 nucleofilaments, and complete blocking of homologous recombination repair (HR) | Prolonged exposure to Cr(VI) suppresses HR, increasing reliance on error-prone DNA DSB repair pathways and the potential for mutation | Browning et al. (2016); Browning and Wise (2017)
WTHBF-6 human bronchial fibroblasts | 0.1, 0.15, and 0.2 μg/cm^2^ zinc chromate (0.12, 0.18, and 0.24 ppm), 24, 48, 72, 96, and 120 hr | Time-dependent increases in DNA damage and DNA DSB signaling, decreases in Rad51 foci formation.; Cr(VI)-induced suppression of E2F1 transcription factor for Rad51 is involved | | Qin et al. (2014), Speer et al. (2021)
Aneuploidy and genomic instability
Primary human fibroblasts | 0, 2, 20, and 40 μg/L (0.01, 0.102, and 0.205 μM) K_2_CrO_4_, 24 hr | Using 24 color M-FISH: ↑ chromosomal aberrations (structural and numerical), dose-dependent; Simple and complex aneuploidy was observed at all doses, dose-dependent | Slowly resolved with time up to 30 d postexposure | Figgitt et al. (2010)
BJ normal human foreskin fibroblasts, hTERT + and − | 0.04, 0.4, and 4 mM Cr (VI) (K_2_Cr_2_O_7_), 24 hr | In hTERT-deficient cells, 30 d postexposure:; Persistent induction of dicentrics, nucleoplasmic bridges, micronuclei and aneuploidy; ↓ clonogenic survival; ↑ β-gal staining and apoptosis | Cr(VI) induced persistent genomic instability; Telomerase-positive cells were not affected except for persistent tetraploidy | Glaviano et al. (2006)
Human MRC-5 cells | 0, 0.25, 0.5, 1, 2, and 4 μM K_2_Cr_2_O_7_, 30 h | ↑ kinetochore-positive micronuclei | Authors determined aneuploidy caused by malsegregation at anaphase and not by nondisjunction | Güerci et al. (2000); Seoane and Dulout (1999); Seoane and Dulout (2001); Seoane et al. (2002)
WTHBF-6 human bronchial fibroblasts | 0.5 and 1 μg/cm^2^ lead chromate | 24 hr exposure: no effect; 120 hr exposure: ↑ aneuploidy; associated with centrosome amplification | Lead oxide had no effect | Holmes et al. (2006a)
WTHBF-6 human bronchial fibroblasts | 0.1, 0.15, and 0.2 μg/cm^2^ zinc chromate (0.12, 0.18, and 0.24 ppm), 24, 72, and 120 hr | ↑ centrosome amplification; ↑ aneuploidy; Premature centriole disengagement in S and G2, and premature centrosome separation in interphase | | Martino et al. (2015)
Primary human skin fibroblasts | 0.01–100 μM Na_2_CrO_4_ and 0.001–10 μM CaCrO_4_ | ↑ aberrant mitotic spindles and cell division patterns, dose-dependent | | Nijs and Kirsch-Volders (1986)
Primary human peripheral blood lymphocytes | 0.00476 μM and 0.00952 μM K_2_Cr_2_O_7_ | ↑ aneuploidy, dose-dependent; ↑ SCEs, dose-dependent; No change in cell cycle proliferative index | Aneuploidy and DNA repair initiated at very low subtoxic concentrations | Rao et al. (1999)
BEAS-2B human bronchial epithelial cells | 1 μM K_2_Cr_2_O_7_ | ↑ aneuploidy; Subclones induced tumors when injected into nude mice; No microsatellite instability in aneuploid cells; DNA MMR and MLH1 expression was unaffected | | Rodrigues et al. (2009)
WTHBF-6 human bronchial fibroblasts | 0.5 and 1 μg/cm^2^ lead chromate; 72, 96, and 120 hr | ↑ spindle assembly checkpoint bypass (centromere spreading, premature centromere division and anaphase, and ↓ MAD2 levels) | No effect with lead glutamate | Wise et al. (2006)
Human primary and immortalized urothelial cells expressing hTERT (hTU1 cells) | 1–5 μM NaCrO_4_ | ↑ aneuploidy and chromosomal damage in chronic (not acute) incubations in primary and hTERT-immortalized human urothelial cells, dose- and time-dependent | Solid-stain chromosomal analysis could be prone to false positive | Wise et al. (2016)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.3.2.4 Induces epigenetic alterations (KC#4)

Seven studies in humans occupationally exposed to Cr(VI) were identified that evaluated epigenetic alterations in relation to Cr(VI) exposure and mechanistic or apical outcomes, including changes in microRNA levels, global methylation changes, and the methylation of specific genes. The study findings are summarized in Table C-57.

Table C-57 Studies of epigenetic alterations in humans, experimental animals, and human cells in vitro exposed to Cr(VI)

Study overview | Exposure^a^ | Results | Comments | Reference
Exposed: lung tumor samples from chromate workers with lung cancer during surgery or autopsy (n = 36); Referents: lung tumor samples from lung cancer patients without chromate exposure (n = 25) | Exposure intensity ascertained based on work period in chromate industry. Mean (range) of exposure to chromate = 22.61 (12–38) yr | ↑ methylation of CpG sites at APC, mgMT, and hMLH1 genes in chromate lung cancer cases compared with lung cancer referents | Limited description of selection; no consideration of confounders; no confirmation of lack of exposure in referent group. | Ali et al. (2011)
Exposed: factory workers with occupational exposure to chromate (n = 87); Referents: administrative workers from the same factory, without chromate exposure (n = 30); Exclusions: skin infection; cancer; cardiovascular disease; kidney disease; pulmonary disease; history of allergy, asthma, or allergic rhinitis | Air samples collected at 10 locations for 8 hr during regular working hours (flow rate: 1L/min); measurement with atomic absorption spectrometry. Median (IQR) air chromium in exposed group = 15.5 (19.0) μg/m^3^; referent group = 0.2 (0.4) μg/m^3^; Peripheral venous blood collected after work shift; chromium measured by ICP-MS. Mean (IQR) blood chromium in exposed group = 6.4 (7.2) μg/L; referent group = 3.9(1.5) μg/L | ↑ methylation of CpG sites at DNA repair genes (MGMT, HOGG1, XRCC1, ERCC3, and RAD51) in exposed groups | Main limitations are related to lack of description (e.g., for participant selection).; Simultaneous in vitro work demonstrated hypermethylation in human bronchial epithelial 16HBE cells treated with Cr(VI). | Hu et al. (2018)
Exposed: lung cancer cases with chromate exposure (at surgery or autopsy) (n = 23 patients; n = 30 lung cancer tumors); Referents: lung cancer cases with no chromate exposure (n = 38) | Chromate exposures for average (SD) 22.9 (6.9) yr | ↑ methylation of p16 gene in chromate lung cancer compared with lung cancer referents, but nonsignificant (p = 0.528); ↑ methylation of p16 gene with duration of chromium exposure in chromate lung cancer cases (p = 0.064); Chromate lung cancer with methylation of p16 gene had reduced expression of p16 protein (0.076) | Methylation-specific PCR and immunohistochemistry of p16 (tumor suppressor gene).; Smoking affected methylation of p16 gene in referent lung cancer cases only.; No confirmation of lack of chromate exposure in referents.; Small sample sizes, especially for some of the subanalyses based on duration of exposure.; Analyses based on samples – some people contributed multiple samples to the analysis; these would not be independent.; No consideration of confounders. | Kondo et al. (2006)
Cross-sectional study, China.; Exposed: n = 87 workers at a chromate production facility exposed to chromate; Referent: n = 30 workers from same facility, but unexposed to any chromium products | Exposure to Cr(VI) inferred based on occupation.; Also measured total Cr in blood. Blood chromium levels were significantly higher in exposed compared with control subjects. Mean ± SD levels in blood were 14.5 ± 33 and 4.4 ± 1.9 ng/mL in exposed and referent groups, refer to air monitoring (using cellulose filter) as showing all samples <50 μg/m^3^, but data not shown.; The exposed group was divided by the median into two subgroups for high and low exposure. | ↓ miR-3940-5p expression associated with Cr blood level, after adjusting for work duration, gender, age, smoking, drinking, and BMI; ↓ miR-3940-5p & miR-590-5p in exposed group | Main limitations are related to lack of description (e.g., for participant selection). | Li et al. (2014b)
Exposed: chromate workers with lung cancer(n = 26 patients, n = 35 tumors); Referents: lung cancer cases without chromate exposure (n = 26 patients, n = 26 tumors) | Chromate workers exposed to chromate for mean (SD) 22.9 (7.3) yr | ↓ expression of hMLH1 and hMSH2 proteins in chromate lung cancer; In chromate lung cancer group, ↓ expression of nMLH1 in lung cancers with MSI at 3 or more loci | Several samples taken from the same patients – these are not statistically independent.; No adjustment for covariates, though authors noted no significant differences in age, Brinkman score, cancer stage, etc. in the evaluated characteristics.; An additional subanalysis looked at methylation of MLH1 among chromate lung samples, but it was only conducted among 8 samples. 5 of 8 had methylation at hMLH1 gene, and 4 of those 5 also had repression of hMLH1 protein. | Takahashi et al. (2005)
Cross-sectional study, China.; Exposed: n = 29 “healthy” chrome platers employed for at least 1 yr at two facilities; Referent: n = 29 subjects “randomly selected from the healthy workers in the same enterprises and been engaged in public security, support services, or administration work for more than 1 yr, and had no specific chromate exposure history.” | Exposure to Cr(VI) inferred based on occupation. Chrome platers had been employed for at least 1 yr.; Also measured Cr in blood; values were significantly higher among exposed compared with unexposed workers, indicating adequate delineation between groups. Mean (range) values were 15.2 (2.1, 42) in exposed vs. 4.6 (0.2, 28) in referent group. | ↓ methylation of mitochondrial genes (MT-TF, MT-RNR1) in chromium-exposed workers compared with controls; No difference in methylation level of LINE-1 or in mtDNA copy number between groups | Limitations are the limited and poorly described statistical analysis, and limited description (e.g., for participant selection). Small sample size.; Inconsistent results might indicate the influence of other occupational hazards on micronuclei concentrations. | Linqing et al. (2016)
Exposed: individuals (n = 115; 29 females, 86 males) with exposure to sodium dichromate for at least 6 mo; Referents: healthy volunteers (n = 60; 15 females, 45 males) in the same city without chromate exposure history; Exclusions: medical history of liver or renal disease, hypertension, diabetes, cardiovascular disease, or pregnancy | Air-Cr concentration collected with point dust sampler and measured with electrothermal atomic absorption spectrometry.; Personal air samples collected through full shift (8 hr) sampling to calculate cumulative dose; Postshift blood samples collected; chromium measured with ICP-MS; mean (SD) chromium in blood of exposed workers = 12.45 (20.28) μg/L; ↑ accumulation of Cr in peripheral red blood cells | Global DNA hypomethylation in chromate-exposed workers | ↑ urinary 8-hydroxy-2-deoxyguanosine, DNA strand breaks.; No adjustment for diet or other nonfolate supplements.; ↓ serum folate in chromate-exposed workers. | Wang et al. (2012)
Rat, Sprague-Dawley | 0, 10.6, 35.4, 106.1 mg/L Cr(VI); 0, 2.49, 7.57, 21.41 mg/kg-d Cr(VI) in drinking water, 4 wk | Mild anemic effects and increased plasma malondialdehyde (MDA) levels occurred in rats exposed to 100 mg/L or 300 mg/L; Plasma glutathione peroxidase (GSH-Px) activity decreased in all exposed groups; Global DNA methylation, p16 methylation; No change in 8-OHdG levels | Mean body weight gain, mean water consumption, clinical chemistry determinations, and oxidative stress levels in plasma. | Wang et al. (2015)
In vitro, 16HBE human bronchial epithelial cells | 0, 0.8, 1.6, 3.1, 6.2, 12.5, 25.0, 50.0 and 100.0 μM Cr_2_O_7_^2−^; 12, 24 or 48 h | ↑ toxicity (>12.5 μM) and DNA damage (comet) (all concentrations), dose-dependent; ↓ p16 expression and hypermethylation of p16 CpG1, CpG31, and CpG32 that correlated with toxicity and DNA damage; ↑ p53 expression without CpG methylation (≥5 μM) | | Hu et al. (2016a)
In vitro, 16HBE human bronchial epithelial cells | 0, 2, 5, and 10 μM Na_2_CrO_4_, 24 h | miR-3940-5p, which normally suppresses XRCC2 and inhibits HR, is downregulated by Cr(VI), enhancing DNA DSB repair | Follow-up study to Li et al. (2014b). Interpreting the effects of one dysregulated miRNA is difficult. | Li et al. (2016)
In vitro, Chinese hamster V79 cells (hpr-1gpt+ transgenic cell line G12) | Potassium chromate | Aberrant DNA methylation silenced G12 cell gpt transgene | | Klein et al. (2002)
In vitro, A549 human alveolar epithelial adenocarcinoma cells and BEAS-2B human bronchial epithelial cells | 0, 5, and 10 μM K_2_CrO_4_, 1 or 24 hr | Global methylation ↑ of histones H3K9 and H3K4 and ↓ H3K27 and H3R2; ↓ MLH1 expression due to hyper-methylation of H3K9 | MLH1 gene codes for DNA mismatch repair protein | Sun et al. (2009)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.3.2.5 Induces oxidative stress (KC#5)

Table C-58 summarizes studies of markers of systemic oxidative stress measured in urine and blood in humans occupationally exposed to Cr(VI). Twenty-three studies were identified.

#### Human studies of systemic oxidative stress

Table C-58 Evidence in human studies prioritized for informing potential Cr(VI)-induced oxidative stress

System | Exposure^a^ | Results | Comments | Reference
Exposed: workers exposed to chromium from chemical, building, and metal industries (n = 40); Referents: age- and sex-matched individuals, unexposed to Cr, living away from incinerators, industries, energy plants, etc. (n = 40) | Assessment: Urinary chromium evaluated from Saturday morning spot samples at end of the work week; assessment with electrothermic atomization-atomic absorption spectrometry.; Levels: Mean (SD) U-Cr (μg/g creatinine) was 0.62 (0.50) among workers and 0.30 (0.13) among controls.; Duration: No information provided about duration of Cr exposure. | In red blood cells of exposed individuals:; ↓ GSH; ↓ GSH/GSSG ratio; In plasma:; ↓ plasma acid ascorbic levels; ↓ total plasma antioxidant capacity; ↓ TRAP; Null effects on GSSG, DHA, lipoperoxidation (TBA-RM), total thiol levels | Systemic increases in oxidative stress with chromium exposure. | De Mattia et al. (2004)
Exposed 1: Cement workers in building construction (n = 22 males); Exposed 2: Tannery workers (n = 20 males); Referent: “normal healthy” volunteers (n = 23 males) | Assessment: Blood and urine total Cr measured using inductively coupled optical emission spectrometry; Levels: Highest blood and urine Cr in tannery workers, followed by cement workers, then referents.; [underlined: Group I (control) n = 23]; Blood: 3.81 ± 5.57 μg/L; Urine: 6.27 ± 5.31 μg/L; [underlined: Group II (cement) n = 22]; Blood: 15.27 ± 2.61 μg/L; Urine: 17.22 ± 3.33 μg/L; [underlined: Group III (tannery) n = 20]; Blood: 18.90 ± 1.88 μg/L; Urine: 20.84 ± 1.67 μg/L; Duration: State that “Cement and tannery workers were usually exposed to chromium 8 hr daily for a duration ranged from 1 mo to 40 yr.” | ↑ plasma malondialdehyde; ↓ total thiol; ↑ p53 protein | Unclear if exposure was to Cr(VI) specifically, although more likely for cement workers compared with tannery workers (as described in the discussion section); however, separating effects is impossible, given total Cr was measured in blood and urine. Poor working conditions (e.g., lack of PPE) and co-exposures limit ability to attribute effects to chromium. The population also included adolescents (minimum age 14 yr), which may affect comparability to other studies that only included adults. | Elhosary et al. (2014)
Cross-sectional study, Egypt.; Exposed: n = 41 male electroplating workers exposed to chromium and nickel; Referent: n = 41 male administrative workers at the same facility | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr (and nickel) in serum.; Levels: Serum Cr significantly higher in exposed compared with controls. Mean Cr was 3.30 and 0.23 μg/L in exposed and referent, respectively.; Duration: Exposed workers were required to have worked in electroplating section at least 2 yr, but most worked for considerably longer with mean ± SD = 26.68 ± 11.21 yr. | ↑ 8-OHdG adducts in serum | Exposed and unexposed groups are delineated, although limited description of methods (e.g., participant selection) and known coexposure to nickel could limit inference.; Results correlated with increased micronuclei in buccal cells. | El Safty et al. (2018)
Exposed: workers from bichromate plant with mixed Cr exposure (n = 10); Referents: workers from bichromate plant with no Cr exposure (n = 10), age and alcohol consumption matched to exposed group | Assessment: Urine and blood samples collected at the end of the work week; analyzed with electrothermal atomic absorption spectrophotometer.; Levels: Mean (SD) Cr in whole blood, plasma, and urine of exposed workers: 5.5 (1.2) μg/L, 2.8 (0.4) μg/L, 5.9 (1.1) μg/g creatinine, respectively. Mean (SD) Cr in whole blood, plasma, and urine of referents: 0.7 (0.1) μg/L, 0.7 (0.1) μg/L, 0.7 (0.1) μg/g creatinine, respectively.; Duration: No information on duration of exposure | No difference in 8-OHdG adducts (lymphocytes and urine) or DNA strand breaks (lymphocytes) between exposed and referents | Did not appear to control for key covariates – presents unadjusted results; very small sample size also limits confidence in results. | Faux et al. (1994)
Exposed: chromium-exposed workers (n = 10); Referents: nonexposed workers (n = 10) | Assessment: Urine and blood samples taken from workers at the end of a work week.; Levels: Chromium concentrations in the factory ranged from 0.001 to 0.055 mg Cr(VI)/m^3^ (obtained from personal and area samplers). Mean chromium concentrations in urine (5.97 μg/g creatinine), whole blood (5.5 μg/L), plasma (2.8 μg/L), and lymphocytes (1.01 μg/10^10^ cells) of exposed workers were significantly higher than in nonexposed workers.; Duration: The mean duration of exposure was 15 yr | No difference in 8-OHdG adducts or DNA strand breaks (lymphocytes) between exposed and referents | Also null for DNA strand breaks; authors theorize null findings due to low exposure levels or insensitive measures used (very small sample + low exposure levels – probably very limited power). | Gao et al. (1994)
Exposed 1: Full-time tannery workers (n = 33); Exposed 2: Full- or part-time stainless-steel welders (n = 16); Referents: individuals unexposed to known environmental or occupational carcinogens (n = 30) | Assessment: Spot urine and venous blood samples collected from all subjects on the last day of the work week. Analyzed with graphite furnace atomic absorption spectrophotometer.; Levels: Mean (SD) not reported; Duration: No information on duration of exposure | ↑ lipid peroxidation products (MDA) in urine of welders and tanners; ↓ thiol antioxidants (glutathione) in lymphocytes of welders | Cr levels in plasma correlated with urinary MDA in welders, not tanners, who are primarily exposed to Cr(IIl). | Goulart et al. (2005)
Exposed: Polishers working with chromium-tanned leather (n = 34); Referents: Individuals not employed in industry, free of acute or chronic disease (n = 104) | Assessment: Chromium measured in air at tannery 1978–1990; Levels: Workstation concentrations ranged from mean (SD): 0.023 ± 0.009 mg Cr/m^3^ to 0.11 ± 0.07 mg Cr/m^3^; Duration: Workers exposed to chromium for 3–16 yr | ↑ lipid peroxidation (TBARS) & ↓ Se in plasma in exposed group | Exposure assessment methods likely underestimate actual exposure value; TBARS results potentially confounded by other occupational exposures. | Gromadzińska et al. (1996)
Cross-sectional study, China.; Exposed: n = 87 workers from a single factory in China, who had “occupational exposure to chromate from different work sections”; Referent: n = 30 working in administrative offices without chromate exposure. | Assessment: Exposure to Cr(VI) inferred based on occupation; median duration of employment was 5 yr in both exposed and referent. Also measured total Cr in air samples and in blood.; Levels: Authors state “The concentration of Cr in the air and blood of subjects in the exposure group were significantly higher than the control group (p < 0.001),” which increases confidence in delineation of exposure groups. Geometric mean ± SD of Cr in blood was 8.5 ± 1.3 μg/L in exposed vs. 4.1 ± 1.4 μg/L in referent group, while median (IQR) of air concentrations were 15.5 (19.0) vs. 0.2 (0.4) mg/m^3^.; Duration: Workers had been in the same work section for at least 3 mo and in the factory for at least 1 yr. Median (IQR) yr of working among the Cr group = 5.0 (7.0). | ↑ hypermethylation of CpG sites (in RNA isolated from whole blood), serum 8-OHdG, and MN in peripheral blood lymphocytes in exposed workers compared with referent | Main limitations are related to lack of description (e.g., for participant selection). | Hu et al. (2018); Related studies: Li et al. (2014a); Li et al. (2014b)
Exposed: male chrome-plating workers (n = 25); Referents: unexposed males (administrators and others) (n = 28) | Assessment: Chromium measured in whole blood, urine, and air; blood and urine measured with graphite furnace atomic absorption.; Levels: Mean (SD) concentrations for exposed group: air = 65 (23.6) μg/m^3^; blood = 5.98 (3.17) μg/L; urine = 5.25 (3.03) μg/g creatinine.; Duration: Chrome-plating factory workers had been exposed for 1–12 yr [mean (SD): 5.9 (3.5) yr]. | ↑ Malondialdehyde measured in blood and urine | A strength of this study was that chromium was measured in both air and biological samples.; Limited adjustment for confounders. | Huang et al. (1999)
Exposed: chrome-plating workers (n = 50); Referents: administrative workers, age and SES matched to exposed (n = 50) | Assessment: Chromium in urine samples measured with flameless atomic absorption spectrophotometer with graphite furnace.; Levels: Mean (SD) in exposed group: 10.42 (8.34 μg/g creatinine).; Duration: Chrome plating workers had been exposed to chromium for 15–20 yr. | ↑ Plasma lipid peroxidation; ↓ Erythrocyte antioxidant enzymes | This study is one of the only studies that adjusted for diet in investigating antioxidant enzymes.; High variation of urinary chromium among exposed individuals. | Kalahasthi et al. (2006)
Exposed: lead chromate pigment factory workers (n = 22); Referents: office workers from chromate factory (n = 16) | Assessment: Chromium measured in urine, blood, and air; air sampling for 200 min at flow rate of 2–3 L/min; urine and blood measured with flameless atomic absorption spectrophotometer.; Levels: Chromium in air ranged from below LOD (0.0005 mg/m^3^ among office workers to 0.5150 mg/m^3^ in high exposure area of factory (pulverizing process); mean (SD) chromium among exposed group in blood: 6.75 (3.30) μg/L; in urine: 12.97 (16.31) (μg/g creatinine).; Duration: Mean (SD) duration of work among chromate pigment workers = 9.7 (20.5)* yr. | In blood and sputum:; No difference in 8-OHdG adducts (in respiratory epithelial and white blood cells) between exposed and control groups, or with duration of employment among exposed groups | Chromium levels in blood (which are a marker of recent exposure) were similar between exposed and control groups; this suggests that exposure misclassification could be contributing to the null effects reported in the study.; The authors also suggest that urinary chromium reflects chromium in reduced form, which might not reflect genotoxicity in blood cells.; No adjustment for supplements/vitamins or diet.; *SD appears incorrect | Kim et al. (1999)
Exposed: workers from electroplating plants (3 chromium; 1 nickel-chromium; 2 mixed) (n = 50); Referents: office workers with no previous exposure to chromium (n = 20) | Assessment: Urine samples obtained at end of work shift; analyzed with atomic absorption spectrophotometry. Air chromium measured with personal sampling.; Levels: Mean (SD) urinary chromium among exposed = 5.72 (7.65) μg/g creatinine.; Duration: Electroplaters had been employed for mean (SD): 75.6 (73.1) mo. | ↑ urinary 8-OHdG adducts among exposed group | High degree of variation in urinary chromium levels among exposed group.; Did adjust for some dietary factors (betel nut, alcohol), but this could have been more extensive; no adjustment for supplements/vitamins.; Did not account for coexposures to other metals encountered in the factories, especially the mixed plants | Kuo et al. (2003)
Cross-sectional study, Korea.; Exposed: n = 51 male chrome plating and buffing workers; Referent: n = 31 male office workers from “industrial areas” in South Korea. | Assessment: Exposure to Cr(VI) inferred based on occupation. Also measured Cr in air samples (total and VI), blood, and end-shift urine samples (See Table 1).; Levels: Concentrations in blood and urine were significantly higher in exposed workers, indicating adequate delineation between groups. For example, the geometric mean blood level of Cr was 0.9 and 0.2 μg/dL in exposed and referent workers, respectively. Differently, while air measures were higher for exposed workers the difference was not statistically significant.; Duration: Mean duration of occupational exposure was 9.1 yr (range: 1 mo–40 yr). | ↑ lipid peroxidation (TBARS) in plasma; ↑ frequency of chromatid exchange, chromosome/chromatid breaks and exchanges, and of translocations, correlated with higher blood Cr; ↑ frequency of translocations in exposed compared with unexposed | Main limitations are related to lack of description for analysis and results reporting. | Maeng et al. (2004)
Exposed: Electroplaters (n = 90), evenly split among near bath workers, degreasers, and washers; Referent: Quality control personnel in same facilities (n = 30) | Assessment: Air samples (locations not specified) used to measure Cr(VI) using spectrophotometer.; Levels: Median Cr(VI) exposure level was highest in near bath (0.38 mg/m^3^) followed by degreasers (0.20 mg/m^3^) and washers (0.05 mg/m^3^); levels were below the LOD for referent workers.; Duration: Median (IQR) working yr among exposed = 4.5 (4.2). | ↑ serum malondialdehyde | Cr(VI) was measured in air samples, which lends confidence that exposure was occurring and at significantly higher levels in exposed workers vs. referents. | Mozafari et al. (2016)
Exposed: Electroplaters (n = 105 males); Referent: office workers (n = 125 males) | Assessment: Air samples from personal breathing zones used to measure Cr(VI) using UV-visible spectrophotometer (also measured total Cr); values combined with duration of employment to estimate cumulative exposure. Total Cr was measured in urine, hair, and fingernails using graphite furnace atomic absorption spectrophotometry.; Levels: Total and Cr(VI) in air were higher in exposed workers (see Table 2); for example, the geometric mean daily cumulative Cr(VI) was 155.6 (GSD = 3.3) in exposed vs. 4.8 (GSD = 1.9) μg/m^3^ in referents. Total chromium in biosamples was also significantly higher.; Duration: Mean (SD) working yr among exposed group = 9.4 (5.6). | ↑ urinary 8-OHdG; ↑ urinary malondialdehyde | The sample size is larger compared with other similar studies, and Cr(VI) was measured in air samples, which lends confidence that exposure was occurring and at significantly higher levels in electroplaters vs. referents. | Pan et al. (2017)
Exposed (direct): cement production unit factory workers (n = 60); Exposed (indirect): administrative workers in cement production factory (n = 28); Referents: healthy individuals from nearby city (n = 30) | Assessment: Serum chromium measured with platform partitionate varian graphite furnace.; Levels: Mean (SE) serum chromium in direct exposed group: 5.2 (0.4) μg/L.; Duration: mean (SE) yr of employment direct exposed = 4.7 (0.08); indirect exposed = 4.5 (0.17). | ↓ TTM & TAC; No difference in TBARS or NO (indicators of lipid peroxidation) | No evaluation of air chromium levels; very limited consideration of covariates. | Pournourmohammadi et al. (2008)
Exposed: individuals (n = 115; 29 females, 86 males) with exposure to sodium dichromate for at least 6 mo; Referents: healthy volunteers (n = 60; 15 females, 45 males) in the same city without chromate exposure history | Assessment: Air-Cr concentration collected with point dust sampler and measured with electrothermal atomic absorption spectrometry. Personal air samples collected through full shift (8h) sampling to calculate cumulative dose. Postshift blood samples collected; chromium measured with ICP-MS.; Levels: Mean (SD) chromium in blood of exposed workers = 12.45 (20.28) μg/L; Duration: Mean (SD) yr of employment among exposed group: 12.86 (6.02); range: 1–33. | ↑ urinary 8-OHdG, DNA strand breaks and global DNA hypomethylation in chromate exposed workers; ↑ accumulation of Cr in peripheral red blood cells & ↓ serum folate in chromate-exposed workers | No adjustment for diet or other nonfolate supplements. | Wang et al. (2012)
Exposed: chromium platers (n = 35); Referents: healthy subjects with no history of disease or previous exposure to chromium or other metals (n = 35) | Assessment: Personal exposure monitoring for 8-h working shift (1.71/min) on only 10 individuals in the exposed group.; Blood and urine samples collected at end of shift and analyzed with atomic absorption spectrophotometry.; Levels: Individual time-weighted average range: 0.049–1.130 mg/m^3^.; Duration: The mean duration of employment was 6.5 yr. | Significantly lower SOD levels in Cr workers (6.86 ± 0.80 U/mg Hb) compared with controls (7.16 ± 0.53 U/mg Hb) (p < 0.01) | Also ↑ sister chromatid exchange and percent high frequency cells in exposed group compared with controls.; Personal air sampling only obtained for n = 10 individuals in the exposed group; SCE analysis conducted based on work group rather than measured exposure level.; Unable to draw conclusions about effect of genotype due to small sample size. | Wu et al. (2001)
Cross-sectional study, Austria.; Exposed: n = 22 bright chrome plating workers exposed to chromium and cobalt; Referent: n = 22 jail wardens | Assessment: Exposure to Cr(VI) inferred based on occupation. Welders used mainly TIG process (95%) with smaller proportions of electric arc and very little autogenous welding.; Also measured Cr in whole blood; levels were higher in welders compared with controls.; Levels: Mean + SD levels for exposed workers at the beginning and end of the work week were 1.4 + 0.9 and 2.3 + 1.5 μg/L, respectively, while values for referent were 0.2 + 0.2 μg/L; Duration: All workers worked for 8 hr per day 3 wk before and during the sample collection | No changes (slight but not statistically significant) in plasma malondialdehyde, oxidized low density lipoprotein, and total antioxidant capacity (TEAC) (biochemical parameters of redox status) | Limitations are due to small sample size and presence of coexposures, which precluded more detailed analysis to separate effects.; ↑MN and rates of Nbuds in buccal and nasal mucosal cells. | Wultsch et al. (2014)
Exposed: n = 319 living in villages with historic Cr contamination; Referents: n = 307 living in villages without historic Cr contamination | Assessment: Cr measured in groundwater (7-m or 8-m deep wells), soil (field surface), and air (24 h/d for 5 d in both exposed and unexposed villages).; Levels[median (min, Q1, Q3, max): Groundwater mg/L exposed: 0.002 (0.002, 0.002, 1.1, 2.5), n = 13; unexposed: 0.002 (0.002, 0.002, 0.002, 0.002), n = 18; Soil mg/kg exposed: 69.5 (48.7, 59.1, 93.9, 417.1), n = 45; unexposed: 29.2 (20.1, 26.4, 30.4, 41.11), n = 30; Air ng/m^3^ exposed: 19.3 (10.1, 13.7, 28.4, 82.9), n = 15; unexposed: 13.12 (5.0, 10.9, 16.8, 18.7), n = 15; Duration: Mean (SD) yr of residence: 45 (13). | In serum of exposed group:; ↑ MDA (p < 0.001); ↑ Catalase activity (p < 0.001); ↑GSH-Px activity (p < 0.001); ↑ 8-OHdG (p = 0.008); ↓ SOD activity (p < 0.001) | Systemic increases in oxidative stress observed with increasing chromium exposure. | Xu et al. (2018)
Exposed: Electroplaters (n = 117) at one of five different metal factories; Referent: office workers (n = 45) | Assessment: Total Cr in urine measured using graphite atomic absorption spectrophotometry.; Levels: Urine Cr was higher in exposed compared with referent (mean [SD] of 0.74 [0.53] vs. 0.34 [0.18] μg/g creatinine, respectively).; Duration: individuals with <9 yr of exposure: mean (SD) = 8 (2); individuals with >10 yr of exposure = 10 (8). | ↑ urinary 8-OHdG | Unclear if exposure was to Cr(VI) specifically (possible with electroplaters but seem to have measured total Cr in urine). Also, while difference in mean urine Cr was significant, the levels seem somewhat low. Coexposures with nickel, did not exclude smokers (high prevalence), and significantly higher alcohol consumption among exposed workers may affect results. | Yazar and Yildirim (2018)
Exposed: Electroplaters at 7 workshops in Tehran (n = 30 males); Referent: Age- and sex-matched dairy production workers (n = 30 males) | Assessment: Blood Cr levels measured using flameless atomic absorption spectrometer.; Levels: Blood Cr higher in exposed vs. referent (mean [SD] = 5.97 [1.74] vs. 4.22 [0.08] ng/mL), increased from 4.42 μg/L to 10.6 μg/L.; Duration: Work duration 1–10 yr. | ↑ lipid peroxidation; ↓ plasma antioxidant capacity; ↓ plasma total thiol (SH groups) | Unclear if exposure was to Cr(VI) specifically (possible with electroplaters). Also, while difference in mean blood Cr was significant, the levels were more similar than expected between exposed and referent. | Zendehdel et al. (2014)
Exposed: electroplating workers (n = 157); Referents: individuals without exposure to chromium or known physical/chemical genotoxic agents (n = 93) | Assessment: Air-Cr and blood Cr determined by graphite furnace atomic absorption spectrophotometer.; Levels: median (range) Cr in erythrocytes (μg/l) among exposed: 4.41 (0.93–14.98); among controls: 1.54 (0.14–4.58). Median (range) short-term concentrations of Cr in air: 0.060 (0.016–0.531) mg/m^3^.; Duration: Median (min–max) yr of exposure among exposed group: 5.3 (0.5–23). | ↑ urinary 8-OHdG adducts among exposed compared with referents; ↑ DNA damage (measured by the comet assay) in lymphocytes among exposed compared with referents | Limited adjustment for confounders (including diet).; Potential coexposures to other metals in the workplace. | Zhang et al. (2011)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

#### Human in vitro studies of oxidative stress

Table C-59 summarizes in vitro studies of markers of oxidative stress in response to Cr(VI) exposure. Because all in vivo animal studies of oxidative stress following Cr(VI) exposures focusing on organ- or tissue-specific oxidative stress are already categorized within the health effect section for supporting evidence relevant to the study (i.e., respiratory, GI, hepatic, hematological, male or female reproductive, developmental), they have not been repeated here. In vitro studies of oxidative stress induced by Cr(VI) were included if they were conducted in human primary cells or immortalized human cell lines and not already summarized in another health effect section.

Table C-59 In vitro studies of Cr(VI)-induced oxidative stress

System | Exposure^a^ | Results | Reference
Human chronic myelogenous leukemic (CML) K562 cells, promyelocytic leukemic HL-60 cells, and normal human peripheral blood mononuclear (HPBM) cells | 12.5 and 25 μM Na_2_Cr_2_O_7_, 24 or 48 h | ↓ cytochrome c (↑ SOD); ↑ hydroxyl radical; ↑ intracellular 2,7-DCFD fluorescence; ↑ DNA fragmentation; No apoptosis (TUNEL) in HPBM; ↑ apoptosis in K562 at low dose but necrosis at high dose; Human cultured leukemic cells more sensitive than primary cells | Bagchi et al. (2000b); Bagchi et al. (2001)
Primary human lymphocytes | 0, 50, 100, 200, 600, and 1000 μM K_2_Cr_2_O_7_, 1 h | ↑ DNA strand breaks (comet) (≥400 μM; p < 0.001); DNA damage ↑ with Endo III and ↓ with catalase (p < 0.001), indicating oxidative lesions.; Slight reduction in cell viability (trypan blue exclusion) (viability at top dose was 84.7%) | Blasiak and Kowalik (2000)
Human umbilical vein endothelial cells (HUVECs) | 1–20 mM K_2_Cr_2_O_7_ | ↑ stress response/ inflammatory pathways (JNK, p38 MAPK, NLRP3, ICAM-1, VCAM-1, TNF-α, IL-1β); ↑ intracellular ROS; ↑ apoptosis induced by mitochondrial (intrinsic) pathway | Cao et al. (2019)
Whole human blood | 0.01–40.0 μg K_2_Cr_2_O_7_/mL | ↑ glutathione peroxidase; ↓ SOD, GSH; ↓ ferric-reducing ability of plasma (FRAP) | Dlugosz et al. (2012)
Primary human lymphocytes and erythrocytes | K_2_Cr_2_O_7_ | ↓ GSH, ↑ GSSG and ROS | Husain and Mahmood (2017)
Primary human lymphocytes | 1–100 μM Na_2_Cr_2_O_7_, 1 h | ↑ standard and FPG-modified comet assay DNA strand breaks (≥100 nM); ↑ 8-OHdG (>10 μM); Significant interindividual variation in comet and FPG-comet DNA damage correlated with OGG1 polymorphisms | Lee et al. (2004, 2005)
Primary human fibroblasts | 0.5–500 μM Cr(VI) | ↓ O_2_ consumption, dose-dependent (20–500 μM); ↑ standard and FPG-modified comet assay DNA strand breaks (0.5–3 μM); Attributed to affected mitochondrial function and glucose catabolism | Liu et al. (2010b) (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=1233572)
Human leukemic T-lymphocyte MOLT4 cells | 0–200 μM K_2_CrO_4_, 2 h | ↓ multiple antioxidants, dose-dependent (p < 0.01 at 10 μM); ↑ DNA-protein crosslinks (25 μM); ↑ ROS (DCFH-DA); ↑ DNA-protein crosslinks and protein carbonyls (2 h) and MDA (4 h), dose-dependent; ESR showed reaction of Cr(VI) with NADPH, glutathione reductase or H_2_O_2_-generated Cr(V) and OH radicals; Pretreatment with antioxidants reduced protein carbonyl, MDA and DPC formation but not with catalase inhibitor or riboflavin pretreatments | (Mattagajasingh and Misra, 1995, 1996); (Mattagajasingh and Misra, 1997; Mattagajasingh et al., 2008)
Human diploid fibroblasts | 0, 0.2, 0.5, 1, 2, 3, 5 μM K_2_Cr_2_O_7_ | ↑ DNA strand breaks ≥0.5 μM; Inhibition of excision repair did not prevent repair of breaks.; Scavenging superoxide (SOD) or H_2_O_2_ (catalase) but not hydroxyl radicals (KI) reduced DNA damage; reduced glutathione potentiated damage | Snyder (1988)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate).

### C.3.2.6 Induces chronic inflammation (KC#6)

Mechanistic studies relevant to immunomodulation (including immune stimulation) are summarized in Appendix C.2.5.

### C.3.2.7 Immunosuppression (KC#7)

Mechanistic studies relevant to immunomodulation (including immune suppression) are summarized in Appendix C.2.5. The evaluation of evidence for effects of Cr(VI) on the immune system, presented in Section 3.2.6 of the toxicological review, suggests that Cr(VI) could have immunomodulatory effects that can suppress (as well as stimulate) the immune system. This immunosuppressive effect was primarily determined from a limited number of host resistance assays, and the significance for Cr(VI)-induced carcinogenesis is not currently known.

### C.3.2.8 Modulation of receptor-mediated effects (KC#8)

No evidence exists that Cr(VI) itself has receptor binding activity, although indirectly it can initiate cell signaling cascades involving receptor-mediated pathways (summarized in Appendix C.3.3) and can affect the expression of sex hormone cell receptors (summarized in Appendix C.2.6 and C.2.7).

### C.3.2.9 Causes immortalization (KC#9)

Enabling replicative immortality is a hallmark of cancer and may be informed by studies that indicate inhibition of senescence induced by Cr(VI) exposure. Mechanistic studies reporting endpoints relevant to senescence are summarized in Table C-60.

Table C-60 Mechanistic studies informing Cr(VI)-induced cellular immortalization

System | Exposure^a^ | Results | Comments | Reference
Exposed: male welders (n = 75) and sandblasters (n = 5) from shipyard industry; Referents: subjects from exposed group with chromium blood levels >2 μg/L who underwent intervention to reduce exposure for 5 mo (n = 9) | Shipyard industry welders with mean (range) yr working in industry: 18.5 (2–35).; Chromium measured in blood and urine with atomic absorption spectrometer; mean (range) Cr levels in first sampling period: blood = 0.91 (0.1–6.1) μg/L; rine = 1.33 (0.1–50.2) μg/L | Cr levels in blood and urine associated with ApoJ/CLU glycoprotein levels in serum | Authors conclude the upregulation of Apolipoprotein J/Clusterin glycoprotein that promotes cellular senescence by Cr(VI) is induced by oxidative stress.; Findings differ from earlier study by this group (Katsiki et al., 2004).; Small sample size for the intervention arm of the study. | Alexopoulos et al. (2008)
Exposed: male workers (n = 55 welders; n = 10 sandblasters; n = 15 other) (total n = 80); Referents: nonexposed males of the same age range (n = 30) | Blood and urine samples collected; analyzed with graphite furnace atomic absorption spectroscopy; Higher Cr(VI) in blood (11×) and urine (57×) in welders compared with controls | ↓ serum ApoJ/CLU in exposed; dose-dependent decrease based on level of exposure and duration of exposure | Reduced biomarker of cell survival and senescence Apolipoprotein J/Clusterin; Findings differ from later study by this group (Alexopoulos et al., 2008); Did not appear to adjust for covariates.; Did not provide sample size for subgroup analyses by duration of exposure – difficult to assess confidence in these results. | Katsiki et al. (2004)
L-02 human fetal hepatocytes | 0, 5, 10, 15 μM Cr(VI) | ↑ Clusterin (CLU), dose-dependent | Overexpression of CLU can counteract Cr(VI)-induced MRCC I inhibition, enhancing survival. | Xiao et al. (2019)
Syrian hamster embryo cells | Calcium chromate | ↑ morphological transformation, dose-dependent | | Elias et al. (1991)
Syrian hamster embryo cells | Sodium chromate dihydrate | ↑ morphological transformation | | Dipaolo and Casto (1979)
Balb/3T3, Syrian hamster embryo, R-MuLV-RE cells | Calcium chromate | ↑ morphological transformation | | Dunkel et al. (1981)
Rat liver epithelial cells | Potassium chromate | ↑ morphological transformation | | Briggs and Briggs (1988)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate); chromium trioxide unit conversion: Cr(VI) = 0.52 × CrO_3_.

### C.3.2.10 Alters cell proliferation, cell death, or nutrient supply (KC#10)

Table C-61 summarizes human, animal, and in vitro studies of markers of cell proliferation, cell death, or changes in cellular nutrient supply in response to Cr(VI) exposure. Human occupational and in vivo animal studies and in vitro studies using human primary or immortalized cell lines relevant to cell proliferation and death following Cr(VI) exposures using organ-specific test systems or markers from these systems have already been categorized within the corresponding health effect sections for supporting evidence. Human or animal in vivo studies were included here if they measured any systemic markers of cell proliferation or death or were not previously summarized elsewhere. Similarly, in vitro studies were included if they were conducted in human primary cells or immortalized human cell lines that have not already been summarized in another health effect section. An exception has been made for studies of Cr(VI)-induced changes in cellular energetics. These tables include all identified mammalian in vivo and human in vitro studies that pertain to cellular nutrient supply, regardless of whether they were also reported elsewhere.

Table C-61 Mechanistic studies relevant to Cr(VI)-induced cell death, cell proliferation, and changes in cellular energetics

System | Exposure | Results | Comments | Reference
Cell cycle progression
Human lung fibroblasts (HLFs) | 1 μM Na2Cr2O4, 24 hr | ↑ G1/S and G2/M arrest G1/S checkpoint bypass involves Akt1; ↑ cell survival and ↑ mutation frequency (but ↓ DNA DSBs and CAs) with inhibition of protein tyrosine phosphatase (PTP), mediated by polo-like kinase 1 (Plk1); No change in apoptosis | Plk1 mediates cell cycle checkpoint bypass and mitotic progression leading to increased survival of cells with Cr(VI)-induced DNA damage | Lal et al. (2009); Kost et al. (2012); Chun et al. (2010); Bae et al. (2009a)
Cell death
Exposed: Chrome-plating workers (n = 19); Referents 1: hospital workers (n = 18); Referents 2: university personnel (n = 20) | Total Cr measured in urine, erythrocytes, and lymphocytes using graphite furnace atomic absorption; Total Cr was higher in exposed workers compared with hospital workers (see Table 3; for example, postshift mean urine levels were 7.31 [SD = 4.33] in exposed vs. 0.12 [SD = 0.07] μg/g crt in referent). | In peripheral blood lymphocytes:; No change in apoptosis (nuclear fluorescence measured by FACS flow cytometry); ↑ DNA damage (measured by the comet assay) | Did not exclude smokers (high prevalence) although did present results stratified by smoking (small numbers).; Unclear if exposure was to Cr(VI) specifically (possible with chrome plating workers but measured total Cr in urine). State that previous air monitoring for total chromium showed levels of 0.4 to 5.6 μg/m^3^, which is fairly low. | Gambelunghe et al. (2003)
HLF fetal human lung fibroblasts; L-41 human epithelial-like cells | 1, 2, 5, 10, 15, 20, 25, and 30 μM K_2_Cr_2_O_7_, 2, 24 or 48 hr | ↑ cytotoxicity (MTT assay), dose- and duration-dependent (significant ≥20 μM); ≤5 μM cytotoxicity recovered after 24 hr; Toxicity at 20 μM due to apoptosis (morphology, caspase-3, DNA fragmentation); ↑ ROS (DCFH-DA) at 2 hr; ↑ antioxidant enzymes (glutathione peroxidase, glutathione reductase, catalase) 1–5 μM | Oxidative stress and antioxidant enzymes induced at mildly toxic μM concentrations. | Asatiani et al. (2004); (2010; 2011)
Human chronic myelogenous leukemic (CML) K562 cells, promyelocytic leukemic HL-60 cells, and normal human peripheral blood mononuclear (HPBM) cells | 12.5 and 25 μM Na_2_Cr_2_O_7_, 24 or 48 hr | ↓ cytochrome c (↑ SOD); ↑ hydroxyl radical; ↑ intracellular 2,7-DCFD fluorescence; ↑ DNA fragmentation; No apoptosis (TUNEL) in HPBM; ↑ apoptosis in K562 at low dose but necrosis at high dose | Human cultured leukemic cells more sensitive than primary cells. | Bagchi et al. (2000b); (2001)
Human umbilical vein endothelial cells (HUVECs) | 1–20 mM K_2_Cr_2_O_7_ | ↑ stress response/inflammatory pathways (JNK, p38 MAPK, NLRP3, ICAM-1, VCAM-1, TNF-a, IL-1b); ↑ intracellular ROS; ↑ apoptosis | Apoptosis induced by mitochondrial (intrinsic) pathway. | Cao et al. (2019)
HLF human lung fibroblasts (LL-24 cell line) | 3, 6, and 9 μM Na_2_CrO_4_, 24 hr | ↑ cytotoxicity, duration- and dose-dependent (stat. sig. ≥6 μM); ↑ apoptosis; ↑ p53 (4- to 6-fold); ↑ Cr-DNA adducts | Pretreatment with 1 mM ascorbate or 20 μM tocopherol had no ameliorative effects. | Carlisle et al. (2000a)
HeLa cells | 1, 10, and 100 μM Na_2_Cr_2_O_7_; 1, 2.5, 8, 24, or 48 h | Intracellular Cr(III) inhibits DNA synthesis and replication fidelity by inhibiting DNA synthesome polymerases α, δ, and δ | | Dai et al. (2009)
Human lymphoma U937 cells lacking functional p53 gene | 20 μM Cr(VI), 24 hr | ↑ mitochondria-dependent apoptotic pathway changes (intracellular Ca^2+^, DNA fragmentation, caspase-3, low mitochondrial membrane potential (MMP), and nuclear morphology); ↑ hydroxyl and superoxide anion radicals (measured by ESR-spin trapping); Apoptosis inhibited by NAC; DNA fragmentation suppressed by inhibiting intracellular Ca^2+^ and calpain; No increases in Fas or JNK | Authors conclude Ca(^2+^)-calpain- and mitochondria-caspase-dependent pathways play significant roles in the Cr(VI)-induced apoptosis via the G2/M cell cycle checkpoint. | Hayashi et al. (2004)
Normal human foreskin (BJ) fibroblasts immortalized by human telomerase (BJ-hTERT) | 0–6, 9, or 12 μM Na_2_CrO_4_, 24 hr | ↑ cell cycle arrest; ↓ clonogenic survival, dose-dependent; ↑ % apoptotic cells with dose | | Pritchard et al. (2001)
Primary human lymphocytes | Cr(VI) complexes sodium bis(2-ethyl-2-hydroxybutyrato)oxochromate(V), Na[Cr(V)O(ehba)(2)] and sodium bis(2-hydroxy-2-methylbutyrato)oxochromate(V), Na[Cr(V)O(hmba)(2)] | ↑ apoptosis and ROS and ↓ cell viability with Cr(V) and Cr(VI); Cr(V)-induced apoptosis partially reversed with antioxidants; Cr(V) and Cr(VI) activate Src-family protein tyrosine kinases leading to caspase-3 activation | Cr(VI)-induced apoptosis partially induced by ROS generated by Cr(V) intermediates via SFKs. | Vasant et al. (2001); (2003)
Cellular energetics
BEAS-2B human bronchial epithelial cells | 1 μM Cr(VI), 48 hr | ↑ glycolysis; ↓ respiration; ↓ protein levels of β-F1-ATPase; ↑ GAPDH | Cr(VI) caused shift to fermentative metabolism. | Cerveira et al. (2014)
BEAS-2B human bronchial epithelial cells | 5–20 μM Na_2_Cr_2_O_7_ | ↑ NOTCH1 (Notch1); ↑ CDKN1A (P21); ↓ FBP1 | FBP1, involved in gluconeogenesis, is lost in Cr(VI)-transformed cells.; Reintroduction of FBP1 caused ↑ROS and ↑apoptosis. | Dai et al. (2017a)
L-02 human fetal hepatocytes | 4–32 μM | ↓ mitochondrial respiratory chain complex (MRCC) I and II activity (25 μM) | Cr(VI)-induced MRCC I inhibition activates caspase-3; process dependent on ROS. | (Xiao et al., 2012a; 2012b)
L-02 human fetal hepatocytes | 0, 2, 8, 32 μM Cr(VI), 24 hr | ↑ voltage-dependent anion channel 1 (VDAC1) expression, ROS, and apoptosis with ↓ ATP (32 μM); Effects reversed with NAC pretreatment or blocking VDAC1 | Cr(VI)-induced apoptosis and decreased ATP mediated by ROS and VDAC1. | Yuan et al. (2012)

a Potassium dichromate unit conversion: Cr(VI) = 0.353 × K_2_Cr_2_O_7_; potassium chromate unit conversion: Cr(VI) = 0.268 × K_2_CrO_4_; sodium dichromate dihydrate unit conversion: Cr(VI) = 0.349 × Na_2_Cr_2_O_7_2H_2_O (usually denoted as Na_2_Cr_2_O_7_ because study authors frequently list the salt as the chemical compound even if concentration or dose is based on the dihydrate).

## C.3.3 Gene Expression Studies Relevant to Gastrointestinal Cancer Cell Signaling Pathways

Mechanistic evidence investigating the cell signaling pathways involved in carcinogenesis following exposure to Cr(VI) is summarized in Table C-63. Studies identified in preliminary title and abstract screening as “mechanistic” were further screened and tagged as “cell signaling” if they reported relevant gene expression data. Studies were prioritized if they were (a) oral, inhalation, or intratracheal instillation exposures in vivo, or (b) in vitro exposures in human cells. Two studies in humans, two in vivo studies in rats, and 84 in vitro studies in human cells were identified. This does not include studies reporting toxicogenomic data, which are summarized in Appendix C.3.4.

The human studies, presented in Table C-62, measured increases in p53 expression in the peripheral blood of chromium-exposed workers compared with unexposed workers. Although these studies were not formally evaluated for risk of bias and sensitivity, the potential for coexposures among these workers (Elhosary et al., 2014) or lack of Cr measures in exposed workers (Hanaoka et al., 1997) precludes certainty regarding the potential association between increased p53 expression and Cr(VI) exposure specifically.

Table C-62 Gene expression studies in humans exposed to Cr(VI)

System | Exposure | Results | Reference
Exposed 1: Cement workers in building construction (n = 22 males); Exposed 2: Tannery workers (n = 20 males); Referent: “normal healthy” volunteers (n = 23 males) | Blood and urine total Cr measured using inductively coupled optical emission spectrometry; Highest blood and urine Cr in tannery workers, followed by cement workers, then referents.; Total chromium levels (μg/L) mean ± SD:; Referent (n = 23):; Cr content in blood: 3.81 ± 5.57; Cr content in urine: 6.27 ± 5.31; Cement (n = 22):; Cr content in blood: 15.27 ± 2.61; Cr content in urine: 17.22 ± 3.33; Tannery (n = 20):; Cr content in blood: 18.90 ± 1.88; Cr content in urine: 20.84 ± 1.67; State that “Cement and tannery workers were usually exposed to chromium 8 hr daily for a duration ranged from 1 mo to 40 yr.”; Unclear if exposure was to Cr(VI) specifically, although more likely for cement workers compared with tannery workers (as described in the discussion section); however, separating effects is impossible, given total Cr was measured in blood and urine. Poor working conditions (e.g., lack of PPE) and coexposures limit ability to attribute effects to chromium. The population also included adolescents (minimum age 14 yr), which could affect comparability. | ↑ p53 protein expression (detected by immunocytochemistry) in peripheral blood of tannery and cement workers | Elhosary et al. (2014)
Exposed: chromate plant workers (n = 31 males); Referents: volunteers without occupational chemical exposures (n = 10) | Duration of exposure in workers = 0–23 yr; No assessment of Cr levels in workers or referents | ↑ serum p53 protein expression (detected by ELISA) in serum of chromium workers | Hanaoka et al. (1997)

All other studies were reviewed for effects relevant to the KEGG (Kyoto Encyclopedia of Genes and Genomes, https://www.genome.jp/kegg/pathway.html) “Pathways in cancer” maps for humans (https://www.genome.jp/pathway/hsa05200). Table C-63 summarizes the reference gene IDs and direction of change for each. KEGG pathways are publicly available, manually drawn, and curated pathway maps, based on evidence from recognized evidence-based relationships among genes involved in cancer-related processes. Data from the two rat oral studies or from the 90 in vitro studies in human cells specific to Cr(VI) were then overlayed onto the cancer pathway KEGG maps for rats and humans, respectively, creating two maps (see Figures C-25 and C-26). A third map (see Figure C-27) was created using gene expression changes reported by ToxCast/Tox21 high throughput screening (HTS) assays in human cells exposed to Cr(VI) in vitro. Genes are color coded: red = activation or increased expression, turquoise = inactivation or decreased expression, violet = discordant changes showing both activation and inactivation among different studies, and yellow = proteins that were modified or have changed localization. Green indicates a gene whose expression (or activity of its products) was not tested or not found to have changed.

Figure C-25 KEGG pathways of gene expression changes in rats exposed to Cr(VI) via ingestion.

Red = activated or increased expression; turquoise = inactivated or decreased expression; green = no data or no change detected.

Figure C-26 KEGG pathways of gene expression changes in human cells exposed to Cr(VI) in vitro.

Red = activated or increased expression; turquoise = inactivated or decreased expression; violet = discordant results from different studies; yellow = proteins that were modified or have changed localization; green = no data or no change detected.

Figure C-27 KEGG pathways of gene expression changes in cells exposed to Cr(VI) reported by ToxCast/Tox21 HTS assays.

Red = activated or increased expression; turquoise = inactivated or decreased expression; green = no data or no change detected.

### C.3.3.1 Cell signaling pathways

#### Tissue-specific in vivo animal evidence

The oncogene c-Myc was found to show a dose-dependent increase (protein and mRNA) in the stomach and colon of male Wistar rats after 60 days of exposure to Cr(VI) in drinking water, supporting increased cell proliferation in these tissues (Tsao et al., 2011). The same study also observed decreased stomach and colon expression of the tumor-suppressor p53, MAPK inhibitor RKIP, and Rho-GDIα, which is involved in the Rho-regulated pathways for metastasis/cytoskeleton reorganization. Down-regulation of RKIP led to the activation of MEK/ERK signaling pathway in the rat stomach and colon. Activation of the ERK/MAPK signaling pathway promotes cell proliferation, tumor cell invasion, and angiogenesis and inhibits apoptosis (Guo et al., 2020). Tsao et al. (2011) also reported increased galectin-1. Galectins are associated with gastric cancer cell motility in response to integrin signaling, and galectin-1 is overexpressed in gastric tumor cells and digestive cancers (Wu et al., 2018; Kim et al., 2010). In a separate study, Ki-67—a nuclear protein associated with cellular proliferation, malignant metastasis, and tumor growth (Li et al., 2015a)—showed non-dose-dependent increases in transcript expression in the duodena of mice after oral exposure through drinking water at 11.6 and 31 mg/kg Cr(VI)-day (Rager et al., 2017; Kopec et al., 2012a).

#### In vitro human evidence

In vitro studies in various human cell types demonstrated the role of several processes relevant to the cancer development that include (1) activation of MAPK signal pathway extracellular signal-regulated kinase (ERK), Jun kinase (JNK/SAPK), and p38 MAPK involved in cell proliferation; (2) changes involving DNA damage checkpoint/DNA repair components (e.g., ATM, ATR, XRCC1, RAD17, RAD51, TP53 and DNA-PK); (3) changes in the expression of genes involved in the reactive oxygen species homeostasis (e.g., NFE2L2, NOX, SOD1, SOD2, CAT, GSR); (4) changes in apoptosis-regulating genes (BCL2, MCL1, BBC3, BAX, CASP3, CASP9); and (5) changes suggesting tissue remodeling and epithelial-mesenchymal transition (SNAI2, ZEB1, PLAUR, CDH1, KLF8) and pathways with pleiotropic roles in cancer (NOTCH, HIF-1α, PI3K/Akt).

The effects of chromium exposure were shown to be dependent on cell context and exposure level/time. For instance, exposure to Cr(VI) resulted in considerably different changes in nuclear binding of transcription factors AP-1, NF-κB, SP1, and YB-1 in human MDA-MB-435 breast cancer cells in comparison with rat H4IIE hepatoma cells (Kaltreider et al., 1999). Exposure level/time dependence was shown on transcriptional activity of NF-κB: At low exposure levels of 20 μM for 2 hours, Cr(VI) exposure inhibited both basal and TNF-α-stimulated NF-κB-driven transcriptional activity in human A549 lung adenocarcinoma cells. This inhibition occurred through the interaction of NF-κB with transcriptional coactivators (Shumilla et al., 1999). In contrast, exposures of HepG2 cells to potassium dichromate at 10 μM for 48 hours significantly increased transcription from the NF-κB response element (Tully et al., 2000).

Discordant changes in the expression or activity of certain genes were observed between experiments in cells exposed to cytotoxic levels of Cr(VI) and cells transformed by Cr(VI). This can be exemplified by the expression of BCL2 gene, a founding member of the BCL2 gene family of apoptosis regulators. In immortalized human hepatocytes exposed to cytotoxic levels of Cr(VI), decreased expression of the anti-apoptotic BCL2 gene led to increased apoptosis (Zhong et al., 2017b), while in Cr(VI)-transformed BEAS-2B cells, the BCL2 gene was upregulated, contributing to an apoptosis-resistant phenotype that is consistent with the malignant properties of transformed cells (Medan et al., 2012). These results exemplify the complexity of molecular changes induced by exposure of cells to Cr(VI) and their dependence on exposure level and cellular context.

Table C-63 Gene expression corresponding to positive results of Cr(VI) assays performed in vivo (rats) or in vitro (human cells or TOX21 HTS assays).

Study | Gene symbol | KEGG ID
Rat in vivo studies (Rattus norvegicus)
Bagchi et al. (1997a) | Prkca↑ | 24680
Tsao et al. (2011) | Tp53↓ | 24842
| Arhgdia↓ | 360678
| Pebp1↓ | 29542
| Myc↑ | 24577
| Lgals1↑ | 56646
Human in vitro studies (Homo sapiens)
Abreu et al. (2018) | HSPA1A (Hsp72)↓
| Hsp90α ↓
Adam et al. (2017) | NLRP3↑
| IL1B (IL-1b)↑
Akbar et al. (2011) | IL-2 down↓ | 3558
Antonios et al. (2009) | CD86↑
Asatiani et al. (2004) | CAT (Catalase)↑
| SOD1 (Cu,Zn-SOD)↑
Bae et al. (2009b) | FGR Δ
| ABL1 (ABL) Δ | 25
Barchowsky (2006) | Lck↑
| Fyn↑
Browning and Wise (2017) | Rad51c Δ
| BRCA2 Δ | 675
Cammarota et al. (2006) | MMP2↓ | 4313
| TIMP1 (TIMP)↑
(2000a; Carlisle et al., 2000b) | P53↑ | 7157
Castorina et al. (2008) | ERBB2↑ (24h+) | 2064
| ERBB3↑ (24h+)
Ceryak et al. (2004) | TP53↑ | 7157
| CDKN1A (P21)↑ | 1026
| MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
Chuang et al. (2000) | JNK↑ | 5599
| MAPK11-14 (P38)↑
| MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
Chuang and Yang (2001) | MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
| JUN↑ | 3725
Chun et al. (2010) | Plk1↑
Clementino et al. (2019) | SIRT3↑
| Pink1↑
| PRKN (Parkin)↑
Curtis et al. (2007) | IL1a↑ | 3552
Dai et al. (2017a) | NOTCH1 (Notch1)↑ | 4851
| CDKN1A (P21)↑ | 1026
| FBP1↓
Deloughery et al. (2015) | ATR↑
Ding et al. (2013) | CDH1↓ | 999
| VIM ↑
| FN1↓ | 2335
| CTNNB1 (β-catenin -Δ) | 1499
| SNAI2 (Slug)↑
| Zeb1↑
| KLF8↑
Dubrovskaya and Wetterhahn (1998) | HO↑
Gambelunghe et al. (2006) | TP53↑ | 7157
| CASP3↑ | 836
| CASP8↑ | 841
| CASP9↑ | 842
Ganapathy et al. (2017) | BCl2↑ | 596
| KRAS (Ras)↑ | 3845
Hayashi et al. (2004) | CAPN1 (calpain)↑
He et al. (2013) | IGF1R (IGF-1R)↑ | 3480
| IRS1↑
| HIF1A↑ | 3091
| RELA (NFkB)↑ | 5970
| CXCL8 (IL-8)↑ | 3576
Hill et al. (2008a) | TP53↑ | 7157
| CDKN1A (P21)↑ | 1026
| ATM↑
| PRKDC (DNA-PK)↑
| ATR↑
| AKT1 (AKT)↑ | 207
| MAPK11-14 (P38 MAPK)↑
Hill et al. (2008b) | TP53↑ | 7157
| CDKN1A (P21)↓ | 1026
| PUMA↑ | 27113
| BAX ↑ | 581
| PRKDC (DNA-PK)↑
Hodges et al. (2004) | JUN↑ | 3725
| JNK↑ | 5599
Hu et al. (2018) | MGMT↓
| XRCC1↓
| OGG! (HOGG1)↓
| RAD51↓ | 5888
Kaczmarek et al. (2007) | HIF1A↑ | 3091
Kaltreider et al. (1999) | FOS, JUN (AP1)↑ | 2353, 3725
| NFkB↑ | 5970
| SP1↑ | 6667
| YBX1 (YB1)↑
Kim et al. (2003) | RELA (NFkB)↑ | 5970
Kost et al. (2012) | PTP↓
Lal et al. (2009) | CDKN1B (P27) Δ | 1027
| RB1 Δ | 5925
Li et al. (2016) | XRCC2↑
Liu et al. (2009) | WRN Δ
Lozsekova et al. (2002) | VCL (Vinculin)↓
| TLN1 (Talin)↓
| CDH1 (E-cadherin)↓ | 999
| DSP (Desmoplaktin)↓
Lu et al. (2018b) | STK11 (LKB1)↓
Majumder et al. (2003) | SLC30A1 (Zn-T1)↓
Medan et al. (2012) | BCL2↑ | 596
Myers et al. (2011) | TXN (TRx) Δ
| TXNRD1 (TrxR)↓ | 7296
Nemec and Barchowsky (2009) | STAT1↑ | 6772
| VEGFA↓
| SP1↑ | 6667
Nemec et al. (2010) | Fyn↑
| STAT1↑ | 6772
| IRF1↑
O’Hara et al. (2003) | MAPK8 (JNK)↑ | 5599
| Fyn↑
| Lck↑
O’Hara et al. (2004) | Bmx↑
| PTK2 (Fak)↑ | 5747
| PTK2B (Pyk2)↑
| Fyn↑
| STAT5A, STAT5B (Stat5)↑ | 6776, 6777
| Ap1↑ | 2353, 3725
O’Hara et al. (2005) | STAT3↑ | 6774
| Lck↑
O’Hara et al. (2007) | Lck↑
| STAT3↑ | 6774
| IL-6↑ | 3569
Pritchard et al. (2000) | ICAM1↑
Reynolds and Zhitkovich (2007) | TP53↑ | 7157
Rizzi et al. (2014) | MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
Russo et al. (2005) | BBC3 (PUMA) ↑ | 27113
| PMAIP1 (NOXA)↑ | 5366
| BAX Δ | 581
| CYCS Δ | 54205
| CASP3 ↑ | 836
Shumilla et al. (1999) | RELA (NFkB)↓ | 5970
Shumilla and Barchowsky (1999) | PLAU (uPA)↓
| PLAUR (uPAR)↑
Park et al. (2015) | TP53↑ | 7157
| CDKN1A (P21)↑ | 1026
Park et al. (2016) | ERFFI1↓
Tessier and Pascal (2006) | MAPK11-14 (P38)↑
| MAPK8 (SAPK/JNK)↑ | 5599
| MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
Tully et al. (2000) | TP53↑ | 7157
| FOS↑ | 2353
| RELA (NFkB)↑ | 5970
| AHR↑ (inferred)
| GADD45↑ | 1647
| HSPA1A (HSP70)↑
Vasant et al. (2003) | Lck (p56^lck^)↑
| FYN (p59^fyn^)↑
| Ly(p56/53^ly^)↑
| CASP3↑ | 836
Vilcheck et al. (2006) | FANCD2↑
Wakeman et al. (2005) | MAPK11-14 (P38)↑
Wakeman and Xu (2006) | ATM↑
| SMC1A (SMC1)↑
| ATR↑
| RAD17↑
Wang et al. (2019) | RELA (NFkB, p65) ↑ | 5970
| IL-6↑ | 3569
| HIF1A (HIF-1a)↑ | 3091
Xia et al. (2011) | BTD↓
Xiao et al. (2012b) | MRCCI↓
| HSP1A1 (HSP70)↓
| HSP90AB1 (HSP90)↓ | 3326
Xiao et al. (2012a) | MRCC1, 2↓
| BUB1B (BuBR1)↓
| CDC25A (CDC25)↓
Yang et al. (2017) | MAP1LC3A (LC3II)↑
| Atg12-Atg5↑
| Atg4↑
| Atg10↑
| HMGA1↑
| HMGA2↑
| SQSTM1 (p62)↓
Yi et al. (2016) | STIM1↑
| MAPK3, MAPK1 (ERK1/2)↑ | 5594, 5595
| RELA (NFkB)↑ | 5970
| Ca2+↑ | C00076
Yi et al. (2017) | VDAC1↑
Zeng et al. (2013) | SOD1 (SOD)↓
| GSR (GR)↓
| CAT↓
| NO↓
Zhang et al. (2016) | TP53↑ | 7157
| BCL2↓ | 596
| MCL1 (Mcl-1)↓
| CDK2↓ | 1017
| CCNE1 (Cyclin E)↓ | 898
Zhang et al. (2017) | PI3K/Akt↓
| ER stress
| Mito dysfunction
Zhong et al. (2017b) | ETFDH↓
| SOD↓
| CASP3↑ | 836
| CASP9↑ | 842
| BCL2↓ | 596
| Ca^2+^↑ | C00076
| CYCS Δ | 54205
Zhong et al. (2017a) | SOD1↑
| SOD2↑
| KEAP1↑ | 9817
| NFE2L2 (NRF2) ↑ | 4780
| PPARGC1A (PGC-1a)↑
| NRF1↑
| TFAM↑
| SIRT1↑
| FOXO1↑ | 2308
| AKT1↑ | 207
| CREB1↑
Zuo et al. (2012) | RELA (NFkB)↑ | 5970
| JUN↑ | 3725
| AP1↑
| PTGS2 (COX2)↑ | 5743
Tox21 Assays, Assay ID: DTXSID6032061 (sodium dichromate dihydrate)
TOX21_TR_LUC_GH3_Antagonist | THRB↓
TOX21_SSH_3T3_GLI3_Antagonist | GLI3↓ | 2737
TOX21_p53_BLA_p2_ch2 | TP53↑ | 7157
TOX21_p53_BLA_p2_ratio
TOX21_p53_BLA_p3_ch2
TOX21_p53_BLA_p3_ratio
TOX21_p53_BLA_p5_ch2
TOX21_p53_BLA_p5_ratio
TOX21_GR_BLA_Antagonist_ch2 | NR3C1↓
TOX21_GR_BLA_Antagonist_ratio
TOX21_CAR_Antagonist | NR1I3↓
TOX21_Aromatase_Inhibition | CYP19A1↓
TOX21_RORg_LUC_CHO_Antagonist** | RORC↓
TOX21_PR_BLA_Antagonist_ratio** | PGR↓
TOX21_H2AX_HTRF_CHO_Agonist_ratio** | H2AFX↑
TOX21_ERR_Antagonist** | ESRRA↓
TOX21_ERb_BLA_Antagonist_ratio** | ESR2↓
TOX21_ARE_BLA_agonist_ratio** | NFE2L2↑ | 4780
TOX21_AR_LUC_MDAKB2_Antagonist_0.5nM_R1881** | AR↓ | 367

Direction of change (measuring mRNA or protein): ↑ (upregulated or activated); ↓ (downregulated or inhibited); Δ (protein posttranslational modification or change of intracellular localization).

## C.3.4 Toxicogenomic Studies

Several studies of Cr(VI) exposure measuring toxicogenomic or cell signaling changes were identified in the evidence base. Given the complexity of these studies and comprehensive applicability of the evidence reported an extra level of review and analysis was applied to these studies.

### C.3.4.1 Prioritization of studies for consideration

Full-text screening of 39 mechanistic studies identified as reporting toxicogenomic data was performed; these studies are summarized in Table C-64. Studies were prioritized on the basis of relevance for providing mechanistic insight for Cr(VI)-mediated carcinogenesis in the lung or GI tract. Of these 39 studies, 13 studies were identified that fit these criteria. A further targeted evaluation of these 13 studies was conducted to determine relevance; 8 were prioritized for evaluation in HAWC (the preliminary evaluations of the 5 studies that were not evaluated in HAWC can be found in Appendix C.3.4.3). Of these eight studies selected for evaluation in HAWC, five used the same microarray dataset, so only one evaluation was necessary for these five (details below); an independent analysis using this dataset was also conducted by EPA. In addition to this evaluation (Kopec et al., 2012b), one study in humans occupationally exposed to Cr(VI) (Hu et al., 2017), one additional in vivo animal study (Chappell et al., 2019), and one in vitro study (Huang et al., 2017) were evaluated for risk of bias and sensitivity in HAWC.

Two of the included studies, (Kopec et al., 2012b; Kopec et al., 2012a), generated microarray datasets from tissues collected in female B6C3F1 mice and F344 rat duodenal and jejunal epithelia following 7 and 90 days of exposure to 0.3–520 mg/L (as sodium dichromate dihydrate, SDD) in drinking water, bioassays originally reported by (Thompson et al., 2011b; Thompson et al., 2012c). Five additional studies reported analyses using the same datasets: four from the same research group (Thompson et al., 2012b; 2016; Suh et al., 2014; Rager et al., 2017) and one analysis conducted independently by EPA (Mezencev and Auerbach, 2021). Five of these studies were included in the synthesis of toxicogenomic data analysis; one, Suh et al. (2014), was not included because the scope was restricted to genes involved in iron homeostasis. One study evaluation, pertaining to (1) the quality of the animal study that generated the microarray data, and (2) the quality and usability of the generated microarray, was deemed sufficient to determine confidence in this original dataset, and this could apply to all studies using this dataset. The essential details of this evaluation can be found in the HAWC database under (Kopec et al., 2012b).

The analysis by EPA, described in Mezencev and Auerbach (2021), provides mechanistic insight interpretable toward human relevance of the NTP 2-year rodent bioassays and suggests the existence of potentially vulnerable subgroups. As a part of the independent analysis of this dataset by Mezencev and Auerbach (2021), an evaluation of the microarray data was conducted; these details are described in the following section.

Table C-64 Summary of considered toxicogenomic studies for Cr(VI) overall confidence classification

Author (year) | Species (strain) | Exposure design | Exposure route | Inclusion | Microarray
Hu et al. (2017) | Human study of chromate production workers in China | Cohort | Occupational | Yes, evaluation in HAWC | M
Kopec et al. (2012b) ^a^ | Rat (F344/N), mouse (B6C3F1) | Subchronic | Drinking water | Yes, evaluation in HAWC | H
Chappell et al. (2019) | Mouse (B6C3F1) | Subchronic | Drinking water | Yes, evaluation in HAWC | M
Huang et al. (2017) | Human (BEAS-2B human lung epithelial cell line) | – | In vitro | Yes, evaluation in HAWC | H^b^
Kopec et al. (2012a) | Rat (F344/N), mouse (B6C3F1) | Subchronic | Drinking water | Yes, but not evaluated, same dataset as Kopec et al. (2012b)
Thompson et al. (2012b) | Rat (F344/N), mouse (B6C3F1) | Subchronic | Drinking water | Yes, but not evaluated, same dataset as Kopec et al. (2012b)
Thompson et al. (2016) | Rat (F344/N), mouse (B6C3F1) | Subchronic | Drinking water | Yes, but not evaluated, same dataset as Kopec et al. (2012b)
Rager et al. (2017) | Mouse (B6C3F1) | Subchronic | Drinking water | Yes, but not evaluated, same dataset as Kopec et al. (2012b)
Mezencev and Auerbach (2021) | Mouse (B6C3F1) | Subchronic | Drinking water | Yes, but not evaluated, same dataset as Kopec et al. (2012b)
Sánchez-Martín et al. (2015) | Mouse (C57BL/6J) | Subchronic | Drinking water | No, targeted evaluation below
Izzotti et al. (2002) | Rat (Sprague-Dawley) | Short-term | Intratracheal instillation | Yes, targeted evaluation below
Lu et al. (2018a) | Human (BEAS-2B) | – | In vitro | Yes, targeted evaluation below
Clancy et al. (2012) | Human (BEAS-2B) | – | In vitro | Yes, targeted evaluation below
Chen et al. (2002) | Human (BEAS-2B) | – | In vitro | Yes, targeted evaluation below
Suh et al. (2014) | Rat (F344/N), female; mouse (B6C3F1), female | Subchronic | Drinking water | No, limited scope
D’Agostini et al. (2002) | Rat (Sprague-Dawley) | Short-term | Intratracheal instillation | No, study limited in scope to a subset of genes; same data as Izzotti et al. (2002)
Izzotti et al. (2004) | Rat (Sprague-Dawley) | Short-term | Intratracheal instillation | No, same data as Izzotti et al. (2002)
Madejczyk et al. (2015) | Rat | Acute | Injection-i.p. | No, limited scope
Kumar et al. (2013) | Mouse (Swiss albino) | Acute | Injection-i.p. | No, limited scope
Hamilton et al. (1998) | Chick embryo | Acute | Injection-i.p. | No, limited scope, and model system less relevant to intestinal or respiratory carcinogenesis
Pritchard et al. (2005) | Human (fibroblasts with ectopic expression of h-TERT) | – | In vitro | No, limited scope
Andrew et al. (2003) | Human (BEAS-2B) | – | In vitro | No, limited scope
Joseph et al. (2008) | Human (skin fibroblasts) | – | In vitro | No, model system less relevant to intestinal or respiratory carcinogenesis
Sun et al. (2011) | Human (BEAS-2B) | – | In vitro | No, limited scope
Gavin et al. (2007) | Human (peripheral blood mononuclear cells) | – | In vitro | No, limited scope
Lei et al. (2008) | Rat (lung epithelial cells) | – | In vitro | No, limited scope
Guo et al. (2013a) | Human (skin fibroblasts) | – | In vitro | No, model system less relevant to intestinal or respiratory carcinogenesis
Vaguero et al. (2013) | Human (Alexander hepatoma cells) | – | In vitro | No, limited scope
Guo et al. (2013b) | Acellular protein binding | – | In vitro | No, limited scope
Ovesen et al. (2014) | Mouse (Hepa-1c1c7) | – | In vitro | No, limited scope
Lou et al. (2015) | Human (B lymphoblastoid cells) | – | In vitro | No, limited scope
Johnson et al. (2016) | Yeast (Saccharomyces cerevisiae) | – | In vitro | No, limited scope, and model system less relevant to intestinal or respiratory carcinogenesis
Luczak et al. (2016) | Human (H460 lung carcinoma cell line) | – | In vitro | No, limited scope
Bruno et al. (2016) | Human (BEAS-2B) | – | In vitro | No, limited scope
Hu et al. (2016b) | Human (16HBE bronchial epithelial cell line) | – | In vitro | No, limited scope
Park et al. (2017) | Human (BEAS-2B) | – | In vitro | No, limited scope
Chen et al. (2019b) | Human (16HBE) | – | In vitro | No, limited scope
Hu et al. (2019) | Human (16HBE) | – | In vitro | No, limited scope
Wu et al. (2012) | Human (BEAS-2B) | – | In vitro | No, limited scope

High (H), medium (M), low (L), or uninformative (U).

a This study used animals from Thompson et al. (2011b) and Thompson et al. (2012c). Additional included analyses using the same dataset: Kopec et al. (2012a); Thompson et al. (2012b); Thompson et al. (2016) and Rager et al. (2017). Suh et al. (2014) used same dataset but the analysis was limited in scope.

b Study was high confidence for all reported endpoints except for qPCR, which was determined to be uninformative.

### C.3.4.2 Analysis of data reported by (Kopec et al., 2012b; Kopec et al., 2012a)

Several identified studies used the microarray dataset generated by (Kopec et al., 2012b; Kopec et al., 2012a) from tissues collected in female B6C3F1 mice and F344 rat duodenal and jejunal epithelia following 7 and 90 days of exposure to 0.3–520 mg/L (as sodium dichromate dihydrate, SDD) in drinking water, bioassays originally reported by (Thompson et al., 2011b; 2012c). The exposure levels and tissues were selected based on previously reported significant occurrence of tumors of the small intestines in mice following chronic exposure to Cr(VI) in drinking water (NTP, 2008).

#### Description of the studies and dataset

Mice B6C3F1 were continuously exposed to drinking water containing SDD at target concentrations 0 (control), 0.3, 4, 14, 60, 170, and 520 mg/L SDD until study termination at days 8 or 91, when the animals were euthanized and specimens of intestinal tissues (duodenum, jejunum) and oral mucosa (palate) were collected for gene expression analysis (Thompson et al., 2011b; Kopec et al., 2012a). Tissue collection, isolation of RNA, design and implementation of microarray experiment, and the processing of microarray data have been described in detail (Kopec et al., 2012a). The dataset “Transcriptomic data to assess hexavalent chromium mode of action in mice and rats” is deposited in the Gene Expression Omnibus (GEO) (https://www.ncbi.nlm.nih.gov/geo/) as a Super Series GSE87262. This dataset consists of 394 microarrays from the platforms Agilent-014868 Whole Mouse Genome Microarray 4x44K and Agilent-014879 Whole Rat Genome Microarray 4x44K. The mouse subset of the data was deposited under the accession number GSE87259 and includes 214 microarrays. The data are available in the functional genomics data repository GEO supporting MIAME-compliant data submissions in the form of raw data (.gpr files) and normalized data (normalized following a referenced semiparametric approach).

#### Evaluation of microarray experiment and generated microarray data

A summary of the microarray study design performed by (Kopec et al., 2012b; Kopec et al., 2012a) can be found in Figure C-28. An evaluation of the microarray data reporting quality was conducted using the Minimum Information About a Microarray Experiment (MIAME) (Brazma et al., 2001) (see Table C-65). An evaluation focusing on study design and implementation and on the quality and usability of preprocessed expression data for their reanalysis was also conducted using criteria developed by (Bourdon-Lacombe et al., 2015) (see Table C-66). Additional criteria for DNA microarrays presented by this group were not applied, as this evaluation is not focusing on the reported results of the microarray study.

Figure C-28 Design of microarray experiments conducted by (Kopec et al., 2012b; Kopec et al., 2012a).

Multiplexing of the treatment-control pairs were performed on the same chips, indicating a limited influence of interchip differences in the comparative expression analysis.

Table C-65 Evaluation of the information available with microarray data using MIAME sections

MIAME section | Evaluation of the available information
Part 1: Experimental design | Information provided in sufficient detail. Dose-response type of experiment [0.1, 1.4, 5, 20, 50, 180 mg/L Cr(VI)) in drinking water continuously] with two timepoints (8 and 91 d). Other experimental variables: 3 tissue types (duodenum, jejunum, palate epithelium). Three biological replicates per exposure level/tissue/timepoint.
Part2: Array design | Information available due to the commercial nature of microarray platform. Commercial microarray Agilent-014868 Whole Mouse Genome Microarray 4x44K (www.agilent.com). Designed to represent all known genes in the mouse genome and their resulting transcripts, the microarray comprises 41,534 60-mer oligonucleotide probes representing over 41,000 mouse genes and transcripts.
Part 3: Samples | Information provided in sufficient detail.; [underlined: Organism:] Mus musculus strain B6C3F1; sex = female; 6–7 wk old at exposure.; [underlined: Sample:] RNA (isolation and evaluation of purity and integrity reported).; [underlined: Labeling:] Following manufacturer’s protocol.
Part 4: Hybridizations | Information provided in sufficient detail. Hybridization was performed following manufacturer’s protocol (Agilent Manual: G4140-90050 v. 5.0.1). Information on the dye swap and hybridization design reported adequately (see Figure C-28).
Part 5: Measurements | Reported sufficiently. Original scans: not available (these are usually not provided). Raw data provided. Normalized data provided as a gene expression matrix. Normalization approach (a semi parametric) was reported and properly referenced.
Part 6: Normalization controls | Included in microarray design.

Table C-66 Evaluation of the DNA microarray experiments in (Kopec et al., 2012b; Kopec et al., 2012a) using criteria outlined by Bourdon-Lacombe et al. (2015)

Criterion | Status for (Kopec et al., 2012b; Kopec et al., 2012a)
Mandatory or important criteria important in evaluating the overall quality of toxicogenomics experiments
Control animals were handled alongside treated animals using identical procedures (e.g., controls in oral gavage experiments received vehicle only) and at similar times. | True. No additional variable (including time) was identified between exposure groups and corresponding controls.; (Equivalent to confounding/variable control and exposure domains in the study evaluation in HAWC.)
A minimum of three biological replicates (animals) were used per group. | True for all exposures/tissues/timepoints with single exception for mice-duodenum-90-d-1.4 mg/L Cr(VI) exposure and control groups (2 replicates available only). This deficiency affects only 1 of 18 tissue-exposure groups from 90 d mouse study. The impact is limited.
If temporality is considered, time-matched controls were used. | True. Two timepoints have separate time-matched controls. In fact, each exposure group even has separate unexposed controls.
The appropriate animal model and tissue was used, and a rationale is given for the doses selected. | True. The study used the same mouse strain and exposure levels as previous NTP bioassay (2007f); NTP (2008) and focused on the tissues (duodenum, jejunum) in which the NTP study detected pathological changes of interest. (The same as the exposure design domain in the study evaluation in HAWC).
If dose–response is considered for risk modeling (including estimation of the BMD), a minimum of three doses plus control was used; ideally, at least one of these doses should be near the NOAEL. | True. Six doses plus control were employed. LOAEL for duodenal epithelial hyperplasia in female mice was at 5 mg/L Cr(VI) exposure in 2 yr NTP bioassay (38% cumulative incidence). The evaluated study included much lower exposures [1.4 mg/L and 0.1 mg/L Cr(VI), and shorter time].
Tests to assess various toxicities (e.g., histopathology, biomarkers of disease) were done using the same biological samples. | Partially true. Animals from the same study and exposed under the same conditions were used for histopathology evaluation and other phenotypic assays of target tissues.
Criteria that are required or should be considered in DNA microarray methodologies
RNA A260/A280 ratios are reported and are above 1.8 to indicate sample purity or are consistent across samples. | Partially true. Determination of the purity of RNA by A260/A280 has been indicated in the text, but the values have not been reported.; This reviewer’s experience is that these values are frequently determined and used to assess the quality of RNA preparations, but they are usually not reported, because of irrelevance of their actual values with respect to publication (if >1.8, the RNA is used for downstream experiments; If not, RNA is isolated again). This reviewer considers the fact that the ratio has been determined and used to assess the purity of RNA as sufficient even if its value is not reported.
The integrity of RNA was assessed [common strategies include an RNA integrity number (RIN), an RNA quality indicator (RQI) or 28s:18s ratio] to ensure minimal RNA degradation or consistency across samples. | True. Determination of the RNA integrity was performed using denatured gel electrophoresis. This is an older and more laborious, but less expensive method than using a lab-on-a chip (e.g., Agilent Bioanalyzer), which provides a specific RIN score. This reviewer considers the fact that the integrity of RNA was verified by denatured electrophoresis as sufficient.
When multiple microarrays are necessary and the experiment was run over different days, the samples were randomized across the slides/days to avoid confounding effects (often referred to as a block design). Note: not always specified in the methods. | Of three biological replicates for given exposure level, one exposure and one control specimen were always hybridized on the same microarray slide. Three replicates were spread across three different slides. This design ensures that even if each of these 3 slides is processed on a different day, the confounding due to batch effect can be eliminated if the data are analyzed with consideration for pairing of specimens on the same slides. The information on timing of microarray processing was not provided; nevertheless, the batch effect can be identified through data analysis (if present), and under some circumstances it can also be corrected.
Generally, gene annotation and data quality are more robust when commercially produced microarray platforms are used. | True. Commercial microarray platform has been used.
Species appropriate microarrays were used (i.e., mouse arrays for mouse samples). | True. Mouse microarray Agilent-014868 Whole Mouse Genome Microarray 4x44K has been used.
Labeling and hybridization were done according to manufacturer protocol. Any deviations are reported. | True. Manufacturer’s protocol has been reportedly followed (Agilent Manual: G4140-90050 v. 5.0.1), and no deviation was indicated.
When cohybridizations of treated and control samples are done (use of different fluorophores for control and treated samples), dye-swapping experiments were done, or that dye bias was assessed statistically is indicated. | True. Dye-swapping was performed (see Figure C-28; green and red colors represent Cy3 and Cy5 dyes).
Scanner specific quality control software was used to test microarray quality. | True. GenePix Pro 6.0 software was used for data collected by GenePix 4000B scanner. All data has reportedly passed quality control. The results of quality control assessment were not presented (which is not unusual in the field).
Data quality was assessed (through MA plots, heat maps, boxplots, scatterplots, signal to noise ratio, etc.). | Partially true. Heatmaps for duodenal and jejunal data for 8 d and 90 d timepoints with hierarchical clustering on specimens were provided [Figures 6 (8 d) and 8 (91 d), (Kopec et al., 2012b)]. This is not an unsupervised analysis and only differentially expressed genes were analyzed. This reviewer does not consider this criterion to be “a hard criterion.” Data quality plots can be usually re-created when needed and assessed by study evaluator.
In the case that outliers are identified, a minimum of three replicates per group remain and a justification for removal has been provided. | Partially true. In one specific tissue/exposure combination, only 2 replicates are available. An explanation for the missing replicates was not provided, but it is not certain that the replicates represented outliers (it could have been a technical failure affecting 2 specific microarrays). Other than that, removal of other microarrays was not identified.
The data were preprocessed (e.g., background subtracted and log transformed) and normalized (i.e., adjusted to remove technical variations between arrays) prior to statistical analysis. | True. Preprocessed data were submitted to the GEO repository.
Data files were made available through an open access public database such as Gene Expression Omnibus (GEO), Chemical Effects in Biological Systems (CEBS) or ArrayExpress). | True. See GEO https://www.ncbi.nlm.nih.gov/geo/); SuperSeries GSE87262.

##### Distribution of normalized expression intensities (from GEO)

The dataset for the mouse small intestine reported by (Kopec et al., 2012b; Kopec et al., 2012a) was further analyzed. Distributions of normalized expression intensities were retrieved using the GEO2R tool (see Figures C-29 through C-32). The distributions demonstrate that the values submitted by the study authors are median-centered and therefore cross-comparable.

Figure C-29 Signal intensity boxplots for 8-day exposure mouse data (duodenum, top dose excluded).

Due to the limitation in number of boxplots, this image does not include 520 mg/L SDD [180 mg/L Cr(VI)] exposure and control group. Note: 1 mg/L SDD = 0.349 mg/L Cr(VI).

Figure C-30 Signal intensity boxplots for 8-day exposure mouse data (duodenum, top 4 dose groups).

The image includes top 4 exposure groups and corresponding controls. Note: 1 mg/L SDD = 0.349 mg/L Cr(VI).

Figure C-31 Signal intensity boxplots for 90-day exposure mouse data (duodenum).

The image includes all exposure groups and corresponding controls for 4 – 60 mg/L SDD. Note: 1 mg/L SDD = 0.349 mg/L Cr(VI).

Figure C-32 Signal intensity boxplots for 90-day exposure mouse data (duodenum).

The image includes all exposure groups and corresponding controls except for 4 mg/L SDD exposed and control groups. Note: 1 mg/L SDD = 0.349 mg/L Cr(VI).

##### Principal component analysis

Principal component analysis was performed to visualize multidimensional gene expression data and identify relationships among specimens. This analysis was executed using BMDExpress 2.20.0148 BETA (Sciome, 2018) separately for 8-day and 91-day mouse duodenum gene expression data. The data were normalized and log2-transformed. This method reduces high-dimensionality of microarray data (41,268 signal values per microarray) onto 2-dimensional space with orthogonal variables PC1 and PC2 that capture the maximum amount of variance. The 8-day exposure duodenal data show separation for three highest exposure levels along PC2 (see Figure C-33). The 90-day data show separation only for two highest exposure groups (combined) and 4.61 mg/kg-day group from all other groups (see Figure C-34). The results suggest separation of microarray data by exposure, which is more pronounced in the 8-day than in the 90-day dataset and for higher but not for lower exposure levels.

Figure C-33 Principal component analysis of 8-day exposure data for mice and duodenal tissues.

Exposure levels [mg/kg-day Cr(VI)] are color-coded.

Figure C-34 Principal component analysis of 90-day exposure data for mice and duodenal tissues.

Exposure levels [mg/kg-day Cr(VI)] are color-coded.

##### Hierarchical clustering

Hierarchical clustering was performed with the GENE-E tool (Broad Institute) for all mouse-related data with GEO accession number GSE87259 (see Figure C-35). Data used were all signal intensities normalized by the study authors; distance metrics were 1- Pearson correlation coefficient; the linkage method was average. Separation between 8-day and 90-day data was forced through their separate analysis by hierarchical clustering.

The result of this unsupervised clustering displays clear separation of overall gene expression of palate specimens from duodenum and jejunum for both 8-day and 91-day exposures, which is consistent with expected biological differences. Duodenum specimens for 8-day exposure to 520 mg/L clearly separate from all other duodenum and jejunum specimens. Duodenum specimens [8 day/20–60 mg/L Cr(VI)] and jejunum specimens [8 day/20–180 mg/L Cr(VI)] cluster together but separately from those exposed to 0.1–5 mg/L Cr(VI) for 8 days. Low exposures [0.3 mg/L and 1.4 mg/L Cr(VI)] tend to cluster together with vehicle controls. In 90-day data, duodenum and jejunum specimens from mice exposed to the highest concentrations of Cr(VI) (60 mg/L and 180 mg/L) form a well-defined cluster with separation between duodenum and jejunum specimens.

Figure C-35 Hierarchical clustering of microarrays from duodenum, jejunum, and palate tissues from mice exposed to SDD for 7 days and 90 days.

This visualization cannot provide adequate resolution and serves only for illustrative purposes. Text color coding: Green-exposed, gray-controls. Colored squares: red – duodenum, beige – jejunum, blue – palate; yellow – 8 days, violet – 91 days. Expression color coding: blue-low, red-high. For a higher resolution image, see (U.S. EPA, 2022a).

The study that generated microarray dataset GSE87259 does not substantiate major concerns with respect to the risk of bias. The only potential issue, which has been identified, is apparently incomplete outcome data due to the discrepancy between the number of mice reportedly allocated to the gene expression study and the number of mice needed to produce the dataset GSE87259. This discrepancy is possibly of little significance because the number of allocated mice has been reported in an article that was not actually reporting microarray data generation, processing, or interpretation (Thompson et al., 2011b). The study authors could have refined the design of the microarray study and eventually processed less mouse tissue for gene expression analysis than originally planned. Issues specific to reporting and design of the microarray experiment were of little significance with respect to the quality and usability of data for toxicogenomic analysis. The results of the principal component analysis of normalized data supplied by study authors demonstrated that the microarrays are cross-comparable among different dose levels for a given tissue type and exposure time, which supports their use for transcriptomics BMD determination and for analysis of gene expression differences between exposed and control animals within the same tissue type.

In addition, the expression data were found to be similar for jejunum and duodenum based on the results of unsupervised hierarchical clustering. This clustering presents relationships among specimens by a tree whose branch lengths reflect the degree of similarity in the overall gene expression between specimens. Moreover, the jejunum and duodenum were found to differ considerably from palate tissue with respect to overall gene expression. This finding is consistent with expectations based on biological differences and supports the quality of microarray data through biological plausibility. Furthermore, duodenum specimens [8-day, 20–60 mg/L Cr(VI)] and jejunum specimens [8-day, 20–180 mg/L Cr(VI)] were shown to cluster together but separately from the same specimens isolated from mice exposed to 0.1–5 mg/L Cr(VI). This finding supports the existence of dose dependence of overall expression data and implies the existence of differences between low and high exposure groups. Interestingly, the low exposures 0.1 mg/L and 1.4 mg/L Cr(VI) tend to cluster together with vehicle controls. Thus, the result of hierarchical clustering shows consistency with biological expectations (support for quality of microarray data) and identifies meaningful natural classes among specimens.

Another issue not addressed by this evaluation is related to the use of single-channel data from two-color microarrays used in accordance with a two-color protocol and with cohybridization of Cy-3 and Cy-5 labeled specimens. During a discussion with collaborators, a concern was raised that Cy-3 only data were used, but Cy-5 data were excluded from further analysis. The study authors argued in their report that Cy-5 data can be unreliable due to sensitivity of this dye to ambient ozone. This issue has been recognized by the scientific community and the means for its remediation are available from the microarray supplier (Agilent). Most likely, these means have not been used by the study authors and they have decided to disregard affected Cy-5 data after the experiment was completed. Therefore, it is unlikely that this approach does not represent a selective reporting that increases the risk of bias. Although some concerns could remain with respect to the data processing, separate channel analysis for two-channel microarrays has been explored and recommended by other investigators (Smyth and Altman, 2013).

This evaluation did not address the raw gene expression data and their preprocessing due to time and resource limitations. Nevertheless, a collaborator was able to process raw data using a code supplied by the study author and demonstrate reproducibility of the raw data processing through independent generation of the same normalized data as supplied by study authors to the GEO [personal communication].

### C.3.4.3 Targeted study evaluations

The following five studies were prioritized for relevance for providing mechanistic evidence informative to Cr(VI)-mediated carcinogenesis in the lung or GI tract, but preliminary targeted evaluations determined that full study evaluations in HAWC were not warranted. Because these have not been included in the HAWC database, the limited preliminary evaluations have been provided below.

#### Lu et al. (2018a)

A full study evaluation to judge the potential risk of bias is not warranted. The source of BEAS-2B cells was not reported, and the description of transformation of cells is very limited, missing any narrative on how the cell culture changed during the 6-month incubation, whether the cell growth was evaluated in the process, or how often cultures had to be subcultured, which are all good practices to report for development of new cells by long-term exposures. Small, medium, and large colonies were reportedly used for implantation in the animal study, but only a large colony from the soft agar assay has been reportedly isolated and maintained as a cell culture, indicating inconsistency in reporting. The growth of tumors seems to be too high for 6-day time after implantation. The concentrations of Cr(VI) at which transformation of cells was achieved were comparable to those used in similar studies, equivalent to 0.037 mg/L and 0.074 mg/L of sodium dichromate dihydrate [0.013 and 0.026 mg/L Cr(VI)].

#### Sánchez-Martín et al. (2015)

This study examines changes in (1) histopathology, (2) IHC markers of proliferation (Ki-67) and DNA damage (p-γH2AX), and (3) expression of selected genes by qPCR in the liver and in the proximal (PSI) and distal (DSI) “sections of gastrointestinal tract” of the C57BL/6 J mice exposed to Cr(VI) in drinking water. Mice were exposed to 0, 19, 191, and 1,919 μg/L Cr(VI) for 60 days and subsequently to the same concentration of Cr(VI) in drinking water and 0–125 mg/kg-day B[a]P for 90 days.

This summary addresses the gene expression analysis reported in the study by Sánchez-Martín et al. (2015). Gene expression changes reported in this study are of little informative value due to the reasons indicated below. Even though the study suggests interesting patterns of gene expression with discordant expression changes across anatomical sites and exposure levels, an evaluation is not justified because of considerable reporting deficiencies and the high risk of bias.

- Changes in gene expression are reported only in the form of a heat map. Information about the color coding of expression changes in the heat map is incomplete. No expression values and no statistical tests for significance of their differences are reported.
- The study is not a whole-genome (“omics”) study, and it deals only with expression of selected genes with limited justification for their selection.
- The sample size appears to be 4 animals per exposure level (2 animals of each sex). This design allows identification of only differentially expressed genes that do not show substantial sex differences in response to the Cr(VI) exposure.
- The study uses qPCR for the evaluation of expression of selected genes in the proximal (PSI) and distal (DSI) “sections of the gastrointestinal tract.” These sections are not sufficiently characterized, which allows ambiguous interpretation. The “proximal” and “distal” are indicated to reflect position of the section relative to the stomach, but this does not add sufficient information to ascertain whether only the small intestine or also the colon were examined and which specific segments of these anatomical structures were sampled for downstream analysis.
- The study employs GAPDH as an endogenous control for normalization of the gene expression. The choice of GAPDH is not justified and its invariant expression in the liver and intestine across all exposures has not been demonstrated. There is a lack of confidence for appropriateness of the use of GAPDH as an endogenous control in this study.
- Primers used in the qPCR studies are not reported. Although this information is mentioned as being provided in the supplemental data, the information on the sequences and origin of primers (references, software used for their design, experimental validation of primers) is missing.
- The authors indicate the use of the ΔΔCt method for calculation of gene expression from the qPCR data. Since no information is given on the validation of primers and amplification efficacy for the target genes and an endogenous control, the use of ΔΔCt method is not supported and this method might not be appropriate in this study.

#### Clancy et al. (2012)

The source of BEAS-2B cells is reported; description of transformation of cells is sufficiently reported; growth media and exposure conditions were properly reported; exposure was performed at minimally cytotoxic concentration (0.5 μM) of potassium chromate [0.1 μM Cr(VI)], which does not seem to have been determined in this study but is consistent with other reports. The form of Cr(VI) and its source are reported (potassium chromate, Sigma). The cells have been altered by Cr(VI)-mediated transformation (morphology, growth pattern in soft agar), and so sensitivity is not an issue. Methods for mRNA analysis are succinctly described and refer to manufacturers’ protocols. qPCR validation relied on the GAPDH gene as an internal control, which is a frequent practice in the field, but not appropriate without justification (the justification has not been provided in this report). Differentially expressed genes were selected based on t-test p-value of 0.05 and a fold-change cut-offof 1.50. The lack of proper qPCR validation does not invalidate a microarray study using systems biology approaches.

#### Chen et al. (2002)

Sources of BEAS-2B and MEF cells were provided; media composition was reported; sources of vectors pCR-FLAG-IKK, pCR-FLAG-IKK-KM, pcDNA3-myc-IAP1, and pEGFPluc were indicated. The Cr(VI) compound used for this study, however, was not specified. Exposure levels of Cr(VI) were adequately described. For assays other than cytotoxicity/viability, conditions were adequately selected to avoid convolution of the study outcomes with cell death. Likewise, exposure conditions (concentrations, times) were chosen well with respect to sensitivity of outcome detection, as evidenced by demonstrated differences between Cr(VI)-exposed and solvent control cells.

The microarray study employed (1) an old expression array design, (2) only a fold change-based identification of differentially expressed genes, and (3) an unknown number of biological or technical replicates. RT-PCR was used instead of qPCR for validation of selected genes identified by microarray analysis, and endogenous control 7S RNA was used without justification. RT-PCR primer design software, sequences, annealing sites, and amplicon lengths were reported. Reverse transcription conditions were reported but the reverse transcriptase used in the reaction was not described. RT-PCR conditions were reported.

Methods used in this study complemented each other and, in this way, compensated for the identified deficiencies of individual experiments. For instance, deficiencies of microarray experimental design and analysis were compensated by validation RT-PCR and demonstrated IAP-mediated inhibition of cell death in cells exposed to Cr(VI). The somewhat surprising lack of specification of Cr(VI) compound used in this study can be perceived as a critical deficiency rendering most of the study uninformative (at least experiments that employed Cr(VI)-exposure).

#### Izzotti et al. (2002)

Izzotti et al. (2002) analyzed gene expression in Sprague-Dawley rats intratracheally exposed to sodium dichromate^5^ at the dose of 0.25 mg/kg [0.09 mg/kg Cr(VI)] body weight for 3 days and sodium chloride control, using in-house radioactively labeled cDNA microarrays that probed expression of 216 genes tested in duplicates and 5 house-keeping genes. Gene expression was examined in lungs and livers of SDD-exposed and NaCl-exposed (control) groups. Genes were considered differentially expressed if the fold change exceeded 2. This study identified 56 genes overexpressed in lungs of Cr(VI)-exposed rats, which included glutathione metabolism-related genes, membrane channels/transporters, cell signaling molecules, cell cycle-related molecules, stress response/protein folding-related genes, as well as DNA synthesis/DNA repair and apoptosis-related genes. These expression data are consistent with generation of reactive oxygen species, cell proliferation, and inhibition of apoptosis. Protein misfolding-related genes are likely reflecting oxidative protein damage and increased protein synthesis. The study found no changes in gene expression in livers of Cr(VI)-exposed mice relative to control animals, which indicated no significant systemic effects after intratracheal exposure. Although these study results support findings of other toxicogenomic and non-omic mechanistic studies, the study likely provides an incomplete picture of molecular changes induced by Cr(VI) exposure. This is because (1) it evaluated expression of a limited range of genes using in-house produced microarrays, and (2) the dose used in this study [0.09 mg/kg Cr(VI)] failed to induce lung tumors as in other studies in Sprague-Dawley rats exposed 5 times per week over 30 months (Steinhoff et al., 1986).

### C.3.4.4 Toxicogenomic analyses

Toxicogenomic analyses of genome-wide changes in gene or protein expression in response to Cr(VI) exposure can help inform carcinogenic signaling pathways relevant to lung and GI cancer. Four studies were fully evaluated in HAWC: one human study (Hu et al., 2017), two in vivo animal studies (Kopec et al., 2012b; Chappell et al., 2019), and one in vitro study using the human BEAS-2B cell line (Huang et al., 2017), with one evaluation, Kopec et al. (2012b), representing five studies that used the same microarray dataset (see details below). An independent analysis of the published in vivo toxicogenomic data by Kopec et al. (2012b) was conducted by Mezencev and Auerbach (2021) and is described below.

#### In vivo studies

One medium confidence toxicogenomic study was identified in humans. Hu et al. (2017) performed proteomic analysis of sera in male workers recruited from a chromate production facility in China. Primary limitations of this study were the lack of description of participant selection and a relatively small sample size. There were two stages of analysis; first, 25 exposed and 16 unexposed workers underwent “proteomics technology and bioinformatics analysis,” and second, 41 exposed and 25 unexposed workers underwent a validation analysis to confirm findings from the first stage. Sixteen significantly enriched pathways were identified related to innate immune system function, extracellular matrix organization, platelet-related processes, and metabolism (Hu et al., 2017). Notably, the increased abundance of SHH, a gene that promotes tumor growth and metastasis if overactivated, in the sera of Cr(VI) exposed workers is consistent with the potential role of SHH in Cr(VI)-mediated carcinogenesis identified by other toxicogenomic studies (Mezencev and Auerbach, 2021; Huang et al., 2017).

Six of the eight in vivo toxicogenomic analyses in animals after oral exposure to Cr(VI) were published by the ToxStrategies firm. A high confidence study, Kopec et al. (2012b), conducted an analysis of gene expression in the oral mucosa and duodena in tissues collected from female Fischer 344 rats and female B6C3F1 mice exposed to sodium dichromate dihydrate (SDD) in drinking water as described in the original studies by (Thompson et al., 2011b; 2012c). Because the same dataset was used in four other studies published by this group repeated (Thompson et al., 2012b; 2016; Rager et al., 2017; Kopec et al., 2012a), this study evaluation (in HAWC) specific to the original animal studies and the microarray dataset generation was not repeated.

Kopec et al. (2012a) reported gene expression changes in mouse intestinal epithelia after 8 days or 91 days corresponding to oxidative stress, xenobiotic metabolism signaling, glutathione metabolism, cell cycle progression, lipid metabolism, and immune response pathways. In addition, canonical DNA repair pathways (i.e., NER, MMR, and BRCA1) were enriched for genes differentially expressed in the duodena of mice exposed to SDD for 8 days; however, this response was absent in duodena of mice exposed for 90 days and in jejuna of mice exposed for both time periods (Kopec et al., 2012a). A subsequent publication using the same mouse dataset reported gene expression changes indicating reduced apoptosis at day 91 and increased cell growth and proliferation at days 8 and 91 (Rager et al., 2017). Cancer-related signaling identified from the 8-day exposure data largely reflected increased expression of matrix metalloproteases (Mmp2, Mmp7, Mmp9, Mmp10, and Mmp13). Mmp10 and Mmp13 showed dose-dependent upregulation at day 91, which indicated cell migration, tissue remodeling and angiogenesis. In the same study, a parallel analysis of ToxCast/Tox21 and Comparative Toxicogenomics Database (CTD) data for Cr(VI) compounds showed a variety of differences when comparing these in vitro results to the in vivo results for this particular dataset; for example, some pathways associated with DNA damage (e.g., p53) were only activated in vitro (Rager et al., 2017). In a toxicogenomic study in duodena of rats exposed to SDD in drinking water at concentrations up to 180 mg/L, functional analysis revealed enrichment of cell cycle, DNA metabolism, DNA replication, and DNA repair pathways at day 8 but not day 91 (Kopec et al., 2012b). A comparative analysis of the same datasets for rats and mice showed a strong dose-response relationship of the number of differentially expressed genes in the duodenum in both species when total Cr tissue levels exceeded 10mg/kg, with a minimal transcriptomic response in the oral mucosa evidenced by very few gene expression changes showing dose-responsive statistical significance (Thompson et al., 2016).

Additional reports published by this group included a reanalysis of the mouse dataset, limited to 7 of 23 gene categories, which suggested a higher similarity in Cr(VI) induced gene expression changes in the mouse small intestine to expression changes induced by four nonmutagenic carcinogens versus four mutagenic carcinogens (Thompson et al., 2012b). The comparison dataset represented gene expression in rat liver reported by Ellinger-Ziegelbauer et al. (2005). The limited nature of the analysis (cross-species, cross-tissue, and cross-platform comparison of gene expression data for the chemical of interest using a single in vivo study annotated for four mutagenic and four nonmutagenic carcinogens) make the results difficult to interpret.

Another medium confidence gene expression comparison study by the same group using a new dataset reported significant overlap between DEGs induced by oral exposure Cr(VI) and two fungicides, captan and folpet, that also cause intestinal tumors in mice (Chappell et al., 2019). Common pathways modulated by Cr(VI) and the higher concentrations of captan or folpet include those involving HIF1, AP1, PPAR, mTOR 4, and Peroxisome (Chappell et al., 2019). Although these authors suggest the commonalities between two nonmutagenic compounds and Cr(VI) imply a nonmutagenic MOA for Cr(VI)-induced mouse intestinal tumors, concordance among gene expression across these three toxicants does not provide solid evidence for ruling out mechanisms that are not shared by all these toxicants. The study was also limited by a single timepoint and reporting inconsistencies for pathways found to be unique for duodena of Cr(VI) exposed mice.

An independent analysis of the 8- and 91-day B6C3F1 mouse data subset published by ToxStrategies, Inc. (Thompson et al., 2011b; Rager et al., 2017; Kopec et al., 2012b; Kopec et al., 2012a) that was deposited in the Gene Expression Omnibus implicated activation of oncogenic signaling (MYC, MYCN, EGFR, ERBB2, TRIM24) and inhibition of tumor suppressors (CDKN2A, STAT1), which support sustained cell proliferation in the duodenum (Mezencev and Auerbach, 2021) (see Appendix C.3.4.2). Similarly, a parallel analysis of enrichment of the cancer “hallmark” and oncogenic signature gene set collections from the Molecular Signatures Database (MSigDB) identified multiple molecular changes in duodena of mice orally exposed to Cr(VI) known to be relevant for carcinogenesis, including c-Myc targets, E2F targets, and alterations in G2M checkpoint and DNA repair pathways. Gene sets enriched in the duodena of mice exposed for 8 days support angiogenesis, impaired apoptosis, and epithelial-mesenchymal transition, which also represent hallmarks of cancer. Enrichment of the cholesterol homeostasis gene set found for 8-day and 90-day exposures at several exposure levels implies activation of cholesterol biosynthesis that is associated with intestinal crypt hyperproliferation and tumorigenesis. Enriched gene sets from the Oncogenic Signature collection imply oncogenic activation of KRAS, SRC, SHH, and PI3K/AKT/mTOR signaling and inactivation of signaling mediated by tumor suppressors PTEN and RB (Mezencev and Auerbach, 2021).

The analyses by Mezencev and Auerbach (2021) (see Appendix C.3.4.2) also indicate oxidative stress in duodena of mice exposed to Cr(VI) for 91 days through inferred activation of the NFE2L2 upstream regulator. This gene encodes a redox-sensitive transcription factor NRF2, which, upon activation, accumulates in the nucleus where it regulates expression of genes involved in the oxidative stress response (He et al., 2020). In addition, a collection of 26 genes known to be responsive to oxidative stress was also significantly enriched in duodena of mice exposed to Cr(VI) for 91 days. This is in contrast with data after an 8-day exposure, which indicate that this collection of genes was enriched in control mice. As a result, in mice exposed to Cr(VI), lower amounts of ROS are inferred in duodena of mice exposed for 8 days, but higher amounts of ROS are inferred in duodena of animals exposed for 91 days.

Taken together, the results support duodenal carcinogenicity of Cr(VI) ingested in drinking water in mice through activation of oncogenic signaling, inactivation of signaling mediated by tumor suppressors, sustained cell proliferation, oxidative stress, impaired apoptosis, and tissue remodeling.

A notable result of the analyses by Mezencev and Auerbach (2021) was the identification of a potential role for the CFTR (cystic fibrosis transmembrane conductance regulator) in carcinogenesis in mouse small intestines. Toxicogenomic analysis of (Kopec et al., 2012b; Kopec et al., 2012a) datasets by Mezencev and Auerbach (2021) suggested inactivation of CFTR in mice exposed to concentrations of Cr(VI) as low as 0.1 mg/L for 8 days. This inactivation does not appear to be attributable to tissue damage, which was observed in these same animals following subchronic exposure to Cr(VI) concentrations ≥60 mg/L (Thompson et al., 2011b). Therefore, suppression of CFTR activity might represent an early effect of Cr(VI) exposure that contributes to the carcinogenic process. Considering the recently reported tumor-suppressor role of the CFTR gene in mouse and human intestinal cancers (Than et al., 2016), this finding expands the range of plausible mechanisms that could be operative in Cr(VI)-mediated carcinogenesis of intestinal and possibly other tissues, which include mutagenesis, inflammation, or cytotoxicity followed by regenerative proliferation in the carcinogenic MOA of Cr(VI).

Another toxicogenomic study, a limited short-term intratracheal study in rats, was identified. Izzotti et al. (2002) observed gene expression changes in the lung consistent with the generation of reactive oxygen species, cell proliferation, and inhibition of apoptosis. The study found no changes in gene expression in livers of Cr(VI)-exposed mice relative to control animals, which indicated no significant systemic effects after 3 days of intratracheal exposure (Izzotti et al., 2002). The study was determined of limited value, however, due to low exposure levels and to its limited range of genes evaluated by in-house produced microarrays of an old design and therefore was not considered for evaluation in HAWC.

#### In vitro studies

Four toxicogenomic in vitro studies were also identified as particularly informative for Cr(VI)-induced carcinogenicity and cellular transformation. All four studies were partially evaluated (see Appendix C.3.4.3), but only one, Huang et al. (2017), was fully evaluated in HAWC. This study was found to be high confidence for all assays reported in the study, including cell transformation, Western blotting, and an siRNA knockdown, but was determined to be uninformative for qPCR findings due to reporting issues and lack of optimization for this assay.

Clancy et al. (2012) demonstrated transformation of bronchial epithelial BEAS-2B cells exposed to 0.5 μM Cr(VI) for 4 weeks that coincided with differential expression of genes that showed enrichment in several pathways related to cancer development. These included cell mobility and migration, TGFβ receptor signaling, MAP kinase activity, regulation of apoptosis, response to hypoxia, and pathways involved in pancreatic cancer and small-cell lung cancer (Clancy et al., 2012). Transformation of BEAS-2B cells using a similar study design (0.5 μM Cr(VI) for 4 weeks) was confirmed by a separate group that also demonstrated acquisition of a proliferative, migratory, invasive, and tumorigenic phenotype by Cr(VI)-transformed BEAS-2B cells (Huang et al., 2017). In this study, Cr(VI)-mediated transformation was associated with activation of the hedgehog (Hh) signaling pathway, which interplays with multiple oncogenic pathways, and Gli2-mediated inhibition of autophagy. Inhibition of autophagy by Hh signaling activation has been found in the lung cancer cell lines, which support biological relevance of this mechanistic finding. Likewise, a study by Lu et al. (2018a) demonstrated the ability of Cr(VI) to transform BEAS-2B cells exposed to 0.125 μM or 0.25 μM of Cr(VI) for 6 months, which displayed tumorigenicity after subcutaneous injection in nude mice. Proteomic analysis revealed downregulation of STK11 encoded by the tumor-suppressor gene LKB1, suggesting possible activation of Wnt/β-catenin and mTOR signaling pathways that are involved in the development of various cancers. A fourth study demonstrated the importance of NF-κB activation for survival and transformation of cells exposed to Cr(VI), with upregulation of transcriptional targets cIAP1 and cIAP2 (Chen et al., 2002).

## C.3.5 Susceptible Populations

### C.3.5.1 Genetic polymorphisms

#### Summary of evidence in humans

Genetic polymorphisms can alter individual susceptibility to health effects of environmental exposures, including chromium. Several studies in humans occupationally exposed to Cr(VI) have identified polymorphisms in genes related to DNA repair and tumor suppression that were correlated with increased genetic damage and lung cancer. The study findings are summarized in Table C-67 below and discussed in Section 3.2.3.4, “Susceptible populations and life stages.”

Table C-67 Studies of genetic polymorphisms in humans occupationally exposed to Cr(VI)

Study overview | Exposure | Results | Comments | Reference
Cases: workers in chromate factory who developed lung cancer (n = 31); Additional case groups: samples from lung adenocarcinoma (n = 38) and squamous cell carcinoma (n = 46) from individuals never employed in chromate-related industries; Controls 1: workers in chromate factory who did not develop lung cancer (n = 26); Controls 2: randomly selected healthy individuals (n = 89) | Mean (SD) yr of chromate exposure in the workplace: cases = 22.8 (6.56) yr; controls = 20.1 (7.71) yr | ↑ SP-B gene variants in chromate case group & in chromate small cell carcinoma compared with referent small cell carcinoma | SNP genotyping of Surfactant protein B gene.; No evaluation for potential confounding. | Ewis et al. (2006)
Cross-sectional study, Slovak Republic.; Exposed: n = 73 male welders; Referent: n = 71 male controls (administrative officers and hospital employees) | Exposure to Cr(VI) inferred based on occupation.; Mean ± SD duration of occupational exposure was 10.2 ± 1.7 yr.; Also measured Cr in blood.; Exposed workers had average values about twice as high as referent group (stated to be significantly different).; Mean ± SE was 0.07 ± 0.04 vs. 0.03 ± 0.007 μMol/L. | ↑ Cas in individuals with Gln/Gln genotype compared with Arg/Gln or Arg/Arg genotypes in XRCC1 Arg299Gln; more pronounced in Cr-exposed workers | Main limitations are related to lack of description (e.g., for participant selection) and lack of evaluation of confounders aside from smoking. SNP genotyping of genes encoding DNA repair enzymes (XRCC1, XPC, hOGGl). | Halasova et al. (2012)
Cross-sectional study, Slovak Republic.; Exposed: n = 39 male welders; Referent: n = 31 male controls (source not given) | Exposure to Cr(VI) inferred based on occupation.; Mean ± SD duration of occupational exposure was 10.2 ± 1.7 yr.; Also measured Cr in blood.; Exposed workers had average values about twice as high as referent group. Mean ± SE was 0.07 ± 0.04 vs. 0.03 ± 0.007 μMol/L. | ↑ Cas & CTAs in individuals with Gln/Gln genotype compared with Arg/Gln or Arg/Arg genotypes in XRCC1 Arg299Gln | Main limitations are related to sample size, unclear differentiation between exposure groups, and lack of description (e.g., for participant selection). SNP genotyping of genes encoding DNA repair enzymes (XRCC1 and XRCC3). | Halasova et al. (2008)
Cases: chromium-exposed lung cancer patients (n = 45); Controls: hospital patients with no previous malignant disease in medical records or family history; matched on age, gender, and ethnicity (n = 61) | Mean(SD) exposure time in cases: 9.3 (1.7) yr | ↑ odds of hMLH1 polymorphisms in lung cancer cases | SNP genotyping of DNA repair genes XRCC3, hMLHl, and hMSH2.; No detailed information on exposure/occupational history nor were exposure levels quantified; no consideration of confounders. | Halasova et al. (2016)
Exposed: chromate workers with lung cancer (n = 28; n = 38 tumors); Referents: lung cancer patients without chromium exposure (n = 26; n = 26 tumors) | Chromate workers exposed to chromium for mean (SD) 22.9 (6.9) yr | ↑ frequency of RER in lung cancers with chromate exposure compared with without chromate exposure; ↑duration of chromate exposure in chromate lung cancer cases with RER compared with those without RER; ↑ MSI with ↑ duration of chromate exposure; No difference in frequency of LOH in tumors with or without chromate exposure | Multiple samples taken from some chromate exposed patients—these would not be statistically independent.; No consideration of confounders. | Hirose et al. (2002)
Cross-sectional study, France.; Exposed: n = 60 male welders from 36 workshops in the “building trade”; Referent: n = 30 office workers recruited from “general or administration services” without history of occupational exposure to welding fume or other physical or chemical agents | Exposure to Cr(VI) inferred based on occupation. State that <5% of welding was done on stainless steel, which raises concern that total Cr measured in blood and urine may be attributed to Cr(III) exposure.; Also measured total Cr in blood and urine. Cr levels in blood and urine were higher among both groups of welders compared with controls (means 129 to 145, compared with 92 μg/L), and urinary chromium was higher among welders working without smoke extraction systems. | SNP genotyping of DNA repair genes, XRCC1 and XRCC3 XRCC1 variant allele coding Gln amino acid at position 399 was associated with a higher number of DNA strand breaks | Main limitations are related to lack of description (e.g., for participant selection, analysis), unknown contribution of Cr(VI) to Cr exposure and known co-exposures to other metals.; ↑ mean BN % in lymphocytes of welder compared with controls. | Iarmarcovai et al. (2005)
Cross-sectional study, China.; Exposed: n = 120 chromate exposed workers working at a chromate production facility; Referent: n = 97 unexposed workers at same facility (“without contact history of harmful substances”) | Exposure to Cr(VI) inferred based on occupation.; Also measured Cr in whole blood. Cr levels were significantly higher among exposed compared with controls, indicating delineation of exposure.; Median (interquartile range) of Cr in whole blood was 2.81 (3.86) and 0.99 (1.21) μg/L in exposed and referent groups, respectively. | Interaction between micronuclei frequency and SNPs in the following genes: XRCC3, BRCA2, NBS1 | Main limitations are related to lack of description (e.g., for participant selection and statistical analysis) SNP genotyping of XRCC3, BRCA2, NBS1. | Long et al. (2019)
Exposed: workers in a chromate factory (n = 141); Referents: farmers from area approx. 90 miles from chromate factory (n = 54) | Full shift (8 hr) personal exposure sample taken; flow 2.1 min^−1^. Median (IQR) of air Cr(VI) in workers = 17.8 (39.5) μg/m^3^; in referents = 0.06 (0.12) μg/m^3^; Blood samples collected; analyzed with graphite furnace atomic absorption with Zeeman background correction; Median (IQR) of Cr in workers = 6.0 (7.86); 2.64 (2.11) | ↑ accumulation of Cr in RBCs per air Cr(VI) exposure among wild type Band 3 Memphis genotype | SNP genotyping of genes involved in anion transport proteins.; No major concerns with study quality, except for minimal information on participant selection. | Qu et al. (2008)
Cases: chromium-exposed lung cancer patients (n = 50); Controls: Individuals with no previous malignant disease in medical records or family history; age, gender, & ethnicity matched to cases (n = 69) | Mean (SD) exposure time in cases: 9.3 (1.7) yr | ↑ risk of lung cancer with the following genotypes: XPD Lys/GIn+XPC Lys/Gln and XPD Lys/GIn+XPC Gln/GIn | SNP genotyping of XPC(rs2228001), XPD (rs13181,) XRCC1(rs25487), and hOGG1 (rs1052123).; No quantitative assessment of exposure; no adjustment for missing data. | Sarlinova et al. (2015)
Exposed 1: residents of areas contaminated with Cr(VI), asymptomatic with regard to dermal irritation (n = 108); Exposed 2: residents of areas contaminated with Cr(VI), reporting dermal irritation (n = 38); Referents: asymptomatic residents of area with no history of Cr(VI) contamination (n = 148) | Mean (SD) residing at contaminated site (among exposed group): 24.17 (15.23) yr | ↑ OR dermal irritation in GSTM1 null genotype when comparing exposed symptomatic individuals to exposed asymptomatic individuals; ↑ OR dermal irritation in GSTT1 null genotype when comparing exposed symptomatic individuals to control asymptomatic individuals | SNP genotyping of genes (GSTT1, GSTM1, NQO1 and hOGG1) involved in Cr(VI) reduction and fate in cell.; Only adjusted for smoking, not other confounders. | Sharma et al. (2012)
Exposed: chromium workers (n = 35); Referents: age and gender matched controls (n = 35) | Exposure duration ranged from 2 to 14 yr with a mean (SD) of 6.5 (4.2) yr. | ↑ sister chromatid exchanges in exposed group; association with work duration; synergy with smoking; ↑ high frequency cells in exposed groups; synergy with smoking | SNP genotyping for GSTM1 and T1.; Limited sample size. Only adjusted for smoking, not other confounders. | Wu et al. (2000)
Exposed: chromium platers (n = 35); Referents: healthy subjects with no history of disease or previous exposure to chromium or other metals (n = 35) | The mean duration of employment was 6.5 yr.; Personal exposure monitoring for 8-h working shift (1.71/min); blood and urine samples collected at end of shift and analyzed with atomic absorption spectrophotometry; Individual time-weighted average range: 0.049–1.130 mg/m^3^ | ↑ sister chromatid exchange and percent high frequency cells in exposed group compared with controls | SNP genotyping for GSTM1 and T1.; Personal air sampling only obtained for n = 10 individuals in the exposed group. Unable to draw conclusions about effect of genotype due to small sample size. | Wu et al. (2001)
Exposed: electroplating workers (n = 157); Referents: individuals without exposure to chromium or known physical/chemical genotoxic agents (n = 93) | Air-Cr determined by graphite furnace atomic absorption spectrophotometer | ↑ chromium concentrations in erythrocytes among exposed compared with referents; ↑ Olive tail moment, tail length, & tail DNA% among exposed compared with referents | Polymorphisms in XRCC1 and Arg399Gln associated with Cr-induced DNA damage; SNP genotyping for DNA repair genes: XRCC1 Arg399Gln, XRCC1Arg194T rp,ERCC1 C8092A, ERCC5 His1104Asp, ERCC6 Gly399Asp, GSTP1Ile105Val, OGG1 Ser326Cys, XPC Lys939Gln, XPDLys751Gln.; Limited adjustment for confounders (including diet).; Potential coexposures to other metals in the workplace. | Zhang et al. (2012)

a Discrepancy between table and text in the original publication. Values from text noted above; values from table reported as 23.8 (7.0) yr.

#### Carriers of the cystic fibrosis mutant allele

The analyses by EPA [see Mezencev and Auerbach (2021)] of the toxicogenomic data reported in (Kopec et al., 2012b; Kopec et al., 2012a) from mice exposed to Cr(VI) (reviewed earlier in this section) have identified a potential role for CFTR in the carcinogenic effects of Cr(VI). Tumorigenicity of impaired CFTR activity in animal models supports the relevance of the Cr(VI)-mediated inactivation of CFTR for the development of small intestinal tumors in mice exposed to Cr(VI) in drinking water (Than et al., 2016), and CFTR has been shown to act as a tumor suppressor in the human colon (Than et al., 2016). These findings may indicate that carriers of the mutated CFTR allele could be more sensitive to the Cr(VI)-mediated carcinogenicity. In the US alone, more than 10 million people are carriers of a mutated CFTR allele that confers an approximate 50% reduction in CFTR expression levels. Although these individuals do not develop cystic fibrosis, the deficit in CFTR function has been shown to lead to an increased risk for several conditions associated with the disease, including colorectal cancer (OR = 1.44, 95% CI: 1.01–2.05) (Miller et al., 2020). CFTR suppression induced by low Cr(VI) exposures in drinking water can be expected to occur in all exposed populations, but a more significant effect would be expected in humans already producing low levels of this protein. See Section 3.2.3.4, “Susceptible populations and life stages,” for more details.

## C.4 SUPPORTING EVIDENCE FOR EXPOSURE TO THE GENERAL POPULATION

### C.4.1 Drinking Water Data from the Third Unregulated Contaminant Monitoring Rule

Cr(VI) was among 30 contaminants selected for monitoring at public water systems (PWS) for the Third Unregulated Contaminant Monitoring Rule (UCMR 3) between 2013 and 2015 (see Tables C-68–70). A PWS is a network of pipes and conveyances constructed to provide water for human consumption (U.S. EPA, 2006a, b). Small systems, serving 10,000 or fewer people, account for more than 97% of the total number of PWSs, while large systems, serving more than 10,000 people, account for the remaining 3% (U.S. EPA, 2006a, b). A majority of the U.S. population is served by large PWSs [nearly 90% (U.S. EPA, 2006a, b)], and all of them (approximately 4,200) were tested under UCMR 3. For small water systems, approximately 800 systems were randomly selected and used as a representative sample (U.S. EPA, 2012b). Small water systems were omitted from analyses presented in this section. Although most of the public water systems in the United States have reported Cr(VI) concentrations below 1 μg/L, the highest concentrations have approached the MCL (for total chromium) of 100 μg/L. This is 50 times lower than the lowest concentration used in the NTP (2008) bioassay (5 mg/L = 5,000 μg/L). When converting to dose, the lowest doses in rats and mice were 0.2 mg/kg-day and 0.3 mg/kg-day, respectively. By BW^3/4^ scaling,^6^ this would adjust to 0.057 mg/kg-day human equivalent dose for rats and 0.05 mg/kg-day for mice. A standard 70-kg reference human ingesting 2 liters of water/day at 100 μg/L (0.05 mg/L) would ingest a Cr(VI) dose of 0.0029 mg/kg-day. Therefore, the lowest NTP doses are approximately 20 times higher than a potential human drinking water dose at 100 μg/L. This is only an illustrative comparison and does not account for differences in Cr(VI) reduction.

Table C-68 Statistical summary of UCMR 3 chromium (VI) concentrations in large public water systems (PWS)

Parameter (units) | Statistic^a^
Total number of facilities reporting | 3,927
Number of facilities >MRL | 3,573
Number of measurements | 45,712
Average PWS mean (μg/L) | 0.485
Maximum PWS mean (μg/L) | 42.31
Maximum measured value (μg/L) | 97.38
25th %tile of PWS means (μg/L) | 0.0413
50th %tile of PWS means (μg/L) | 0.0963
75th %tile of PWS means (μg/L) | 0.229
95th %tile of PWS means (μg/L) | 1.87
Standard deviation of PWS means (μg/L) | 1.84

a Data below the minimum reporting level (MRL, 0.03 μg/L) are included as ½ the MRL in calculations. Data are from the posted January 2017 release of the EPA Third Unregulated Contaminant Monitoring Rule (UCMR 3) (U.S. EPA, 2014d). Only data collected for large PWSs were used for statistical analysis. Statistics performed on the mean PWS values (each PWS had multiple facilities that collected multiple samples).

Table C-69 Summary of UCMR 3 chromium (VI) concentration data (in μg/L) grouped by EPA region

Region | Count | Mean | Max | Percentiles
Region | Count | Mean | Max | 25th | 50th | 75th | 95th
1 | 237 | 0.131 | 3.80 | 0.0359 | 0.0647 | 0.128 | 0.420
2 | 351 | 0.281 | 23.0 | 0.0432 | 0.0829 | 0.239 | 0.709
3 | 282 | 0.165 | 1.47 | 0.0502 | 0.0899 | 0.189 | 0.513
4 | 905 | 0.124 | 2.42 | 0.0364 | 0.0692 | 0.133 | 0.365
5 | 748 | 0.206 | 3.31 | 0.0265 | 0.126 | 0.199 | 0.751
6 | 432 | 0.521 | 42.3 | 0.0238 | 0.0561 | 0.157 | 1.77
7 | 132 | 0.693 | 3.16 | 0.0475 | 0.277 | 1.19 | 2.35
8 | 162 | 0.273 | 1.99 | 0.0444 | 0.151 | 0.381 | 0.898
9 | 519 | 2.050 | 30.5 | 0.126 | 0.586 | 1.96 | 8.89
10 | 159 | 0.230 | 1.42 | 0.0719 | 0.142 | 0.274 | 0.750

Data below the minimum reporting level (MRL, 0.03 μg/L) are included as ½ the MRL in calculations. Data are from the posted January 2017 release of the EPA Third Unregulated Contaminant Monitoring Rule (UCMR 3) (U.S. EPA, 2014d). Only data for large PWSs were used for statistical analysis.

Table C-70 Summary of UCMR 3 Cr(VI) data for 20 large public water systems with the highest mean concentrations

PWSID | Location | PWSID Name | Mean (μg/L) | Max. (μg/L) | n
OK1020801 | OK | Norman | 42.3 | 97.4 | 80
CA2410005 | CA | City of Los Banos | 30.5 | 38.0 | 8
AZ0407154 | AZ | Town of Buckeye Sundance | 28.8 | 33.0 | 8
AZ0407056 | AZ | AZ American Water Co. – Paradise Valley | 28.0 | 30.1 | 4
AZ0408020 | AZ | Kingman Municipal Water | 25.6 | 79.0 | 24
AZ0407500 | AZ | City of Surprise – Mountain Vista | 23.9 | 39.0 | 16
PR0004074 | PR | Guanica Urbano | 23.0 | 26.3 | 11
CA1010018 | CA | City of Kerman | 19.4 | 31.0 | 16
AZ0407078 | AZ | Valencia Water Co. – Town Division | 18.9 | 22.0 | 15
CA5010017 | CA | City of Patterson | 18.2 | 22.0 | 12
CA5710006 | CA | City of Woodland | 17.7 | 26.0 | 22
CA5710009 | CA | University of California – Davis | 17.5 | 47.0 | 16
OK2001412 | OK | Moore | 17.5 | 54.0 | 47
OK2000922 | OK | Mustang | 15.7 | 29.9 | 12
CA3310007 | CA | City of Coachella | 15.6 | 19.0 | 16
AZ0407695 | AZ | AZ American Water Co. – Agua Fria | 15.0 | 62.0 | 56
AZ0407094 | AZ | Goodyear Water Department | 14.4 | 27.0 | 20
CA5710001 | CA | City of Davis | 14.0 | 41.0 | 32
CA3310020 | CA | Indio Water Authority | 13.0 | 19.0 | 20
AZ0407025 | AZ | City of Phoenix | 12.8 | 54.0 | 80
| | | | Total n = | 515

Data below the minimum reporting level (MRL, 0.03 μg/L) are included as ½ the MRL in calculations. Data are from the posted January 2017 release of the EPA Third Unregulated Contaminant Monitoring Rule (UCMR 3) (U.S. EPA, 2014d). Only data collected for large PWSs were used for statistical analysis.

### C.4.2 Local Data of Air, Soil, and Dust Cr(VI) Concentrations

Because Cr(VI) is classified as a hazardous air pollutant under the Clean Air Act, data for air, dust, and soil are available from state and local environmental departments. Tables C-71 through C-75 list datasets from publicly available sources that were found by screening national, state, and local environmental department websites. These datasets are not from EPA sources, and values are subject to change. Readers are advised to consult the citations and the state websites for the raw data, and detailed information related to data collection and interpretation. This is not an exhaustive summary of all air, dust, and soil Cr(VI) and total chromium (Cr(VI)+Cr(III)) concentrations in the United States.

Table C-71 Cr(VI) concentrations in ambient PM_10_ (ng/m^3^) at monitoring sites in Midlothian, Texas containing three cement manufacturing facilities and a steel mill (ATSDR, 2016)

Location | Mean (confidence interval)
Jaycee Park | 0.016 (0.0094–0.024)
Old Fort Worth Road | 0.055 (0.029–0.086)
Tayman Drive | 0.018 (0.0097–0.035)
Wyatt Road | 0.07 (0.037–0.12)
JA Vitovsky | 0.021 (max)^a^
Midlothian HS | 0.039 (max)^a^
Mountain Peak Elementary | 0.039 (max)^a^

a Maximum value reported only (descriptive statistics not generated by TCEQ because of the small number of observations).

Table C-72 Cr(VI) concentrations in air measured at monitoring sites in Portland Oregon reporting elevated metals concentrations (Oregon DEO, 2016b)

Location | Date | Mean ± SD^a^ (ng/m^3^) | Min | Max
Metal finishing site (Southeast Portland)
Milwaukie Johnson Creek | April–Sept 2016 | 0.321 ± 0.239 | 0.047 | 1.16
SE Harney Dr. | April–Dec 2016 | 0.121 ± 0.118 | 0.038 | 1.01
SE 45th Ave & SE Harney | March 2016–March 2017 | 0.0707 ± 0.0501 | 0.035 | 0.44
Glass producer site (Northeast Portland)
Daycare Center | March 2016–Feb 2017 | 0.201 ± 0.332 | 0.037 | 3.63
Winterhaven Elementary | March–Sept 2016 | 0.0759 ± 0.0604 | 0.037 | 0.695
Powell & SE 22nd | March 2017 | 0.147 ± 0.247 | 0.036 | 3.1
Haig & SE 20th | March 2017 | 0.129 ± 0.316 | 0.038 | 2.88
Reed College | May–Sept 2016 | 0.095 ± 0.0374 | 0.038 | 0.209
Glass producer site (North Portland)
Tubman School | March–Aug 2016 | 0.0625 ± 0.0338 | 0.037 | 0.222
Portland North Coast Electric | March–July 2016 | 0.0993 ± 0.112 | 0.036 | 0.655
Portland Water Bureau East | March–Aug 2016 | 0.118 ± 0.0979 | 0.038 | 0.6
Portland Water Bureau West | March–July 2016 | 0.102 ± 0.0568 | 0.04 | 0.271

a Average daily value as reported by Oregon Department of Environmental Quality, applying the Kaplan-Meir method for nondetects.

Table C-73 Cr(VI) concentrations (mean ± SD in ng/m^3^) in ambient PM_10_ measured in urban and suburban New Jersey (Huang et al., 2014)

Location | Soluble Cr(VI) | | Total Cr(VI)
Location | Summer | Winter | Summer | Winter
Meadowlands | 0.3 ± 0.16 | 0.11 ± 0.04 | 1.25 ± 0.58 | 1.32 ± 0.56
Elizabeth | 0.21 ± 0.13 | 0.19 ± 0.09 | 1.56 ± 0.48 | 1.41 ± 0.56
Rahway | 0.33 ± 0.36 | 0.14 ± 0.07 | 0.99 ± 0.76 | 1.05 ± 0.36
Piscataway^a^ | 0.2 ± 0.18 | 0.03 ± 0.01 | 0.86 ± 0.5 | 0.94 ± 0.49

a Suburban (all other locations urban).

Table C-74 Cr(VI) Mean concentration in air districts with chromium plating and anodizing facilities for the year 2005.

Data from the California Air Resources Board.

District | Monitoring site | Mean concentration (ng/m^3^)
South Coast Air Quality Management District | Azusa-803 Loren Ave. | 0.08
South Coast Air Quality Management District | Burbank – W. Palm Ave. | 0.113
South Coast Air Quality Management District | North Long Beach | 0.10
San Diego County Air Pollution Control District | Chula Vista | 0.038
San Diego County Air Pollution Control District | El Cajon-Redwood Avenue | 0.048
Ventura County Air Pollution Control District | Simi Valley-Cochran Street | 0.05
Bay Area Air Quality Management District | Fremont-Chapel Way | 0.05
Bay Area Air Quality Management District | San Francisco-Arkansas Street | 0.11
San Joaquin Valley Air Pollution Control District | Fresno-1st Street | 0.063
San Joaquin Valley Air Pollution Control District | Stockton-Hazelton Street | 0.12
Sacramento Metropolitan Air Quality Management District | Roseville-N Sunrise Blvd | 0.058

Adapted from CARB (2006).

Table C-75 Estimated environmental concentrations of chromium in selected locations within the United States

Media and location | Units^a^ | Mean | Max. | Reference
Ambient air, Barrio Logan San Diego CA | ng/m^3^ | 0.42 | 22.0 | Residential areas near facilities potentially emitting Cr(VI) from California EPA (CalEPA, 2003, 2004) (May 2001–May 2002)
Ambient air, Portland OR glass and metal sites | ng/m^3^ | N/A | 3.63 | Elevated metals site data from Oregon DEQ (Oregon DEQ, 2016b). See Table 5
Ambient PM_10_, Deer Park and Karnack, Texas | ng/m^3^ | 0.1 | 0.4^b^ | 24-h average data from TCEQ (2006-2013) (TCEQ, 2017)
Ambient PM_10_; soluble+ insoluble Cr(VI), New Jersey | ng/m^3^ | 1.17 | 1.56 | Urban and suburban areas of New Jersey (Huang et al., 2014)
Ambient PM_10_; soluble Cr(VI), New Jersey | ng/m^3^ | 0.189 | 0.33 | Urban and suburban areas of New Jersey (Huang et al., 2014)
Surface soil, Portland OR glass and metal sites | mg/kg Cr(VI) | N/A | 3.0 | Data from Oregon DEQ (Oregon DEQ, 2016a, c)
Surface soil, Portland OR glass and metal sites | mg/kg total chromium | N/A | 63 | Data from Oregon DEQ (Oregon DEQ, 2016a, c)
Background (bulk soil), Montana | mg/kg Cr(III) | 19.5 | 130 | Data from Montana DEQ (Hydrometrics, 2013)
Background (bulk soil), Montana | mg/kg Cr(VI) | N/A^c^ | 1.2 | Data from Montana DEQ (Hydrometrics, 2013)
House dust, New Jersey | μg/g | 4.6 | 56.6 | Background house dust in NJ (Stern et al., 2010) (μg/m^2^ are surface loading units)
House dust, New Jersey | μg/m^2^ | 10 | 169.3 | Background house dust in NJ (Stern et al., 2010) (μg/m^2^ are surface loading units)

a Units of Cr(VI) unless otherwise noted.

b Maximum highest and second-highest hourly measurements are 1.9 and 0.7 ng/m^3^, respectively.

c 88% of values below the limit of detection (<0.29 mg/kg).

1 After 2 days without Cr(VI) exposure, chromium concentration in the plasma will decrease more rapidly than concentration in RBCs. At the same time, chromium will enter plasma from the tissues, which may counteract some of the washout.

2 These are time-weighted average daily doses estimated from NTP (2008) drinking water consumption data during the first 53 weeks of exposure.

3 Reduction capacity is the total amount of Cr(VI) that can be reduced (as t→∞) and is a function of how much reducing agent (components capable of reducing Cr(VI)) is contained in gastric juice. This differs from the reduction rate (how fast Cr(VI) can reduce per unit of time), which is a function of stomach pH.

4 One estimate is that less than 1% of the adult population might exhibit hypochlorhydria, whereas 10%–20% of the elderly population might exhibit this condition (Russell et al., 1993).

5 As with many studies, the compound may be referred to as “sodium dichromate” (Na_2_Cr_2_O_7_), when the compound is administered in an aqueous solution and the mass units are based on sodium dichromate dihydrate (Na_2_Cr_2_O_7_ 2H_2_O). Unless otherwise noted, the conversion factor for sodium dichromate dihydrate (0.349) was used to convert Cr(VI) units for studies labeled as either sodium dichromate or sodium dichromate dihydrate.

6 Assuming rat BW of 0.45 kg, mouse BW of 0.05 kg (based on study-specific data), and human BW of 70 kg.