# APPENDIX B SUMMARY OF OTHER AGENCY CONCLUSIONS

Table B-1 Noncancer inhalation assessments by state, national and international health agencies, and associations (in reverse chronological order)

Reference | Value (μg/m^3^) | Time adjustment | Chemical note | Endpoints/basis
American Conference of Governmental Industrial Hygienists (ACGIH) ACGIH (2017) | 0.2 | 8-h TWA | Cr(VI) inhalable particulate matter | Lung cancer; sinonasal cancer; respiratory tract irritation; asthma. Based on Lindberg and Hedenstierna (1983), with support from other studies (including analyses of Baltimore cohort data by Gibb et al. (2000a, 2000b) and Park et al. (2004).
Texas Commission on Environmental Quality (TCEQ) TCEQ (2014) | 0.0043 | Lifetime/chronic | Particulate compounds | Excess lung cancer mortality risk of 1 × 10^−5^, using risk value derived from Gibb et al. (2000b) and Crump et al. (2003).
Texas Commission on Environmental Quality (TCEQ) TCEQ (2014) | 0.066 | Lifetime/chronic | Particulate compounds | Respiratory effect (increased relative lung weight after 90 d of exposure) in rats (Glaser et al., 1985).
Texas Commission on Environmental Quality (TCEQ) TCEQ (2014) | 0.39 | Acute | Particulate compounds | Respiratory effect (increased relative lung weight after 30 d of exposure) in rats (Glaser et al., 1990).
International Programme on Chemical Safety (IPCS) IPCS (2013) | 0.03 | Lifetime/chronic | Cr(VI) salts | Respiratory effects in rats Glaser et al. (1990).
International Programme on Chemical Safety (IPCS) IPCS (2013) | 0.005 | Lifetime/chronic | Chromium trioxide, chromic acid | Upper respiratory effects in humans (Lindberg and Hedenstierna, 1983).
National Institute for Occupational Safety and Health (NIOSH) NIOSH (2013) | 0.2 | 8-h TWA, 40-h work week | All Cr(VI) compounds | Lung cancer and nonmalignant respiratory effects. Based on analysis of Baltimore cohort data by Park et al. (2004).
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | 0.005 | Chronic | Dissolved aerosols and mists | Upper respiratory effects (nasal irritation/ulceration, mucosal atrophy, and decreases in spirometric parameters), based on Lindberg and Hedenstierna (1983).
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | N/A | Chronic | Particulates | Insufficient data
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | 0.005 | Intermediate | Dissolved aerosols and mists | Upper respiratory effects (nasal irritation/ulceration, mucosal atrophy, and decreases in spirometric parameters), based on Lindberg and Hedenstierna (1983).
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | 0.3 | Intermediate | Particulates | Respiratory tract (lung) and other effects. Based on quantitative analysis of rat studies Glaser et al. (1985); (1990) performed by Malsch et al. (1994).
California EPA Office of Environmental Health Hazard Assessment (OEHHA) CalEPA (2008) | 0.2 | Chronic | Soluble compounds | Respiratory effect (bronchoalveolar hyperplasia) in rats Glaser et al. (1990).
California EPA Office of Environmental Health Hazard Assessment (OEHHA) CalEPA (2008) | 0.002 | Chronic | Chromic trioxide (as chromic acid mist) | Respiratory effects in humans Lindberg and Hedenstierna (1983).
Occupational Safety and Health Administration (OSHA) OSHA (2006b) | 5 | 8-h TWA | All Cr(VI) compounds | Lung cancer and nasal tissue damage. Based on quantitative analysis of Baltimore cohort data by (Gibb et al., 2000a, b) and Luippold et al. (2003).
Dutch National Institute for Public Health and the Environment (RIVM) RIVM (2001) | 0.0025 | Chronic | Inhalable dust | Excess lifetime lung cancer risk of 1 × 10^−4^, based on analysis of human occupational studies by the 1987 and 1994 World Health Organization air quality guidelines.^b^
U.S. EPA, IRIS U.S. EPA (1998) | 0.008 | Lifetime/chronic | Chromic acid mists/dissolved chromium aerosols | Effects in the nasal cavity. Based on Lindberg and Hedenstierna (1983).
U.S. EPA, IRIS U.S. EPA (1998) | 0.1 | Lifetime/chronic | Cr(VI) particulates | Respiratory effects. Based on quantitative analysis of rat studies (1985; Glaser et al., 1990) performed by Malsch et al. (1994).

N/A = not applicable; TWA = time-weighted average.

a Selected values from states known by U.S. EPA to have derived independent values; most states typically adopt values from U.S. EPA.

b Risk value rationale and studies unchanged in WHO (2000).

Table B-2 Cancer inhalation assessments by state, national and international health agencies (in reverse chronological order)

Reference | Risk factor (μg/m^3^)^−1^ | Rationale
Texas Commission on Environmental Quality (TCEQ) TCEQ (2014) | Unit risk factor: 2.28 × 10^−3^ (particulate compounds) | Linearly extrapolated lung cancer risk based on a weighted average of Gibb et al. (2000b) and Crump et al. (2003) (human occupational cohorts).
International Programme on Chemical Safety (IPCS) IPCS (2013) | Occupational exposure risk: 6 × 10^−3^ | Linearly extrapolated lung cancer risk based on Gibb et al. (2000b).
International Programme on Chemical Safety (IPCS) IPCS (2013) | Environmental exposure risk: 4 × 10^−2^ | Linearly extrapolated lung cancer risk based on Gibb et al. (2000b).
International Agency for Research on Cancer (IARC) IARC (2012). | Carcinogenic to humans (Group 1)^b^ | Lung cancer, based on multiple evidence streams. Positive associations between Cr(VI) exposure and cancer of the nose and nasal sinuses in humans also cited.
National Toxicology Program (NTP) NTP (2011) | Known to be human carcinogen^b^ | Cancers of the lung and sinonasal cavity, based on studies in humans.
World Health Organization WHO (2000) | 4 × 10^−2^ | Linearly extrapolated lung cancer risk based on multiple human occupational studies.
IRIS Program, U.S. EPA (1998) | Inhalation unit risk: 1.2 × 10^−2^ | Linearly extrapolated lung cancer risk based on Mancuso (1975, 1997) (human occupational cohort).
California Department of Health Services (CDHS) CDHS (1985) | Inhalation potency: 0.15^c^ | Linearly extrapolated lung cancer risk based on Mancuso (1975).

a Selected values from states known by U.S. EPA to have derived independent values; most states typically adopt values from U.S. EPA.

b Agency does not derive a quantitative risk factor.

c As part of an updated evaluation of the science for the public health goal (PHG), California EPA CalEPA (2011) calculated a slope of 0.16 (μg/m^3^)^−1^ (with a 95% upper confidence of 0.35) using Gibb et al. (2000b), and a lower bound slope of 0.01 (μg/m^3^)^−1^ using Luippold et al. (2003).

Table B-3 Oral assessments by state, national and international health agencies (in reverse chronological order)

Reference | Risk value or limit | Rationale^b^
World Health Organization WHO (2020) [replaces WHO (2003)] | Guideline value: 50 μg/L (total chromium) | Cancer precursor, mouse small intestine hyperplasia
Food Safety Commission of Japan FSC (2019) | Tolerable daily intake: 1.1 × 10^−3^ mg/kg-d | Cancer precursor, mouse small intestine hyperplasia
Health Canada Health Canada (2016) | Maximum acceptable concentration: 50 μg/L | Cancer precursor, mouse small intestine hyperplasia
Texas Commission on Environmental Quality (TCEQ) TCEQ (2016) | RfD: 3.1 × 10^−3^ mg/kg-d | Cancer precursor, mouse small intestine hyperplasia
International Programme on Chemical Safety (IPCS) IPCS (2013) | Tolerable daily intake: 9 × 10^−4^ mg/kg-d | Mouse small intestine noncancer effects
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | Chronic MRL: 9 × 10^−4^ mg/kg-d | Mouse small intestine noncancer effects
Agency for Toxic Substances and Disease Registry (ATSDR) ATSDR (2012) | Intermediate MRL: 5 × 10^−3^ mg/kg-d | Hematological effects (rat data at 22 d)
California EPA Office of Environmental Health Hazard Assessment (OEHHA) CalEPA (2011) | Cancer PHG: 0.02 μg/L | 1 × 10^−6^ cancer risk using OSF of 0.5 (mg/kg-d)^−1^ (mouse small intestine tumors)
California EPA Office of Environmental Health Hazard Assessment (OEHHA) CalEPA (2011) | Noncancer PHG: 2 μg/L | Liver noncancer effects (rats)
California Department of Public Health (CDPH) SWRCB (2014); CDPH (2013) | Proposed MCL: 10 μg/L [see California State Water Board CA State Water Board (2022) fact sheet] | Cancer risk [see California EPA (CalEPA, 2011)]
New Jersey Department of Environmental Protection (DEP) NJ DEP (2009) | Suggested soil remediation criterion: 1 ppm soil concentration | 1 × 10^−6^ cancer risk using OSF of 0.5 (mg/kg-d)^−1^ (mouse small intestine tumors)
Office of Pesticide Programs, U.S. EPA (2008, 2009) | OSF: 0.791 (mg/kg-d)^−1^ | Upper-bound cancer risk estimate (mouse small intestine tumors; mutagenic MOA determined)
Assessments based on science or rules published prior to 2008 National Toxicology Program study
U.S. Food and Drug Administration 2013 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=2316215)) | Allowable level in bottled water: 0.1 mg/L (or 100 μg/L) total chromium | Not specified
U.S. Environmental Protection Agency [Federal Register Federal Register (2010)] | MCL: 100 μg/L (total chromium) | Allergic dermatitis^c^
World Health Organization WHO (2003) [superseded bv WHO (2020)] | 50 μg/L | Provisional value (nonspecific)
Dutch National Institute for Public Health and the Environment (RIVM) RIVM (2001) | 5 × 10^−3^ mg/kg-d | Provisional noncancer effects, based on no-effect level [rats; Mackenzie et al. (1958)]
IRIS Program, U.S. EPA (1998) | RfD: 3 × 10^−3^ mg/kg-d | No effect level for noncancer effects [rats; (Mackenzie et al., 1958)]

MCL = maximum contaminant level; MRL = minimal risk level; OSF = oral slope factor; PHG = public health goal.

a Selected values from states known by U.S. EPA to have derived independent values; most states typically adopt values from U.S. EPA (based on unspeciated total chromium).

b All values based on mouse data from NTP (2008), unless otherwise noted.

c Based on rule promulgated in 1991 (National Primary and Secondary Drinking Water Regulations, 56 FR 3526, 1-30-91 and 54 FR 22062, 5-22-89).

In addition to the (mostly) quantitative assessments above, a qualitative assessment was performed by the Dutch National Institute for Public Health and the Environment (RIVM) on irreversible human health hazards from occupational inhalation exposure to Cr(VI) compounds (Palmen et al., 2018; Hessel et al., 2021; Den Braver-Sewradj et al., 2021). Categorization was restricted to irreversible adverse health effects (likely, possible, insufficient evidence, and unlikely), and focused primarily on inhalation risk (but recognizing that low incidental oral exposure may occur in occupational settings). Health effects that were determined likely in humans were lung cancer, nose and nasal sinus cancer, nasal effects (irritation, ulcerations, and perforation of the septum), chronic lung diseases, respiratory allergy, and allergic contact dermatitis. Stomach cancer was categorized as a possible human health effect from inhalation. Health effects where there was insufficient evidence in humans were immune effects (besides the dermal/respiratory allergies) and reproductive effects (development, fertility, and lactation). Health effects that were determined to be unlikely to occur in humans were larynx cancer, intestinal cancer, gastrointestinal effects, hematological effects, hepatic effects, renal effects, neurological, cardiovascular effects, and dental effects.

Several state, federal, and international agencies have also considered qualitative assessments of the cancer mode-of-action for Cr(VI). These are summarized in Table B-4.

Table B-4 Cancer mode-of-action assessments by state, national and international health agencies (in reverse chronological order)

Reference | Cancer MOA conclusion
U.S. state agencies
North Carolina Department of Environmental Quality (DEQ), Secretaries’ Science Advisory Board (SSAB), Secretaries’ Science Advisory Board response to inquiry on hexavalent chromium, proposed final memo, 2020 Augspurger et al. (2020) | - Comparative weight of evidence analysis of potentially relevant MOAs.; - No MOA determined but acknowledges contribution of mutagenicity: “...both mutagenic and cytotoxic modes of action may result from chemical exposure with mutagenicity occurring at all levels of exposure and as the putative mode of action in the low-dose region.”; - “Multiple modes of action may be occurring simultaneously and the sequence of events leading to cancer formation is uncertain...There is not conclusive evidence to rule out a mutagenic mode of action, and we conclude that Cr(VI) via drinking water exposure may cause mutational changes. Further, remaining uncertainties (e.g., physiologically based pharmacokinetic modeling) are such that we could not definitively choose among the modes of action, and therefore quantitative dose response assessment leading to both an OSF and RfD should be explored by the State. Due to the remaining uncertainty and because it is generally considered to be a more health-protective approach, the SSAB recommends the State consider a linear extrapolation approach.”
Texas Commission on Environmental Quality (TCEQ), Hexavalent Chromium Oral Reference Dose TCEQ (2016) | - Cytotoxicity-induced regenerative proliferation MOA determined (no framework-based MOA analysis).; - Cites (Haney, 2015a) that considers “both the non-linear [sic], non-threshold approach as well as the threshold (i.e., reference dose) approach prior to conducting a weight-of-evidence (WOE) analysis of available MOA data. The WOE indicates that cytotoxicity-induced regenerative hyperplasia is indubitably the most scientifically well-supported MOA. Health Canada (2015) concurs that confidence in a cytotoxic MOA is high (and evidence for a mutagenic MOA is weak). Consequently, the reference dose (RfD) approach is the most scientifically defensible approach based on the WOE of available MOA information and analyses conducted for the most scientifically supported MOA and should be adopted for assessing the potential intestinal carcinogenicity of oral exposure to CrVI (Haney 2015c).”
Texas Commission on Environmental Quality (TCEQ), Hexavalent Chromium Particulate Compounds TCEQ (2014) | - No MOA determined but acknowledges multiple potentially contributing MOAs.; - “...a comparative weight of evidence for various potential MOAs is beyond the scope of this document.” “...the MOA(s) for CrVI carcinogenesis is yet to be fully elucidated, firmly established and widely accepted by the scientific community, although a variety of MOAs have been proposed...The data are simply not sufficient to definitively determine the specific carcinogenic MOA(s).” “...at this time the uncertainties associated with a nonlinear-threshold inhalation carcinogenic assessment for CrVI appear to preclude a robust scientific justification for deviation from the default linear low-dose extrapolation approach.”
California EPA, Office of Environmental Health Hazard Assessment (OEHHA), PHG for Drinking Water, Cr(VI) CalEPA (2011) | - Mutagenic MOA determined.; - Cites MOA analysis by Mccarroll et al. (2010) that used EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a) and the draft Framework for Determining a Mutagenic MOA for Carcinogenicity (U.S. EPA, 2007) and concludes “a mutagenic MOA has been fully described and justified. Unless there are data supporting an alternative mechanism of action, the standard approach for carcinogens operating via a genotoxic or mutagenic MOA is to apply a linearized multistage model to calculate cancer potency (U.S. EPA, 2005; OEHHA, 2009a).”
New Jersey Department of Environmental Protection (DEP), Derivation of Ingestion-Based Soil Remediation Criterion for Cr+6 NJ DEP (2009) | - No MOA determined but acknowledges contribution of mutagenicity.; - “To date, no mode of action has been unambiguously demonstrated for Cr+6 carcinogenicity...The data suggest the possibility of a mutagenic mode of action, and linear extrapolation is also the USEPA recommended approach when a mutagenic mode of action has been demonstrated.”
U.S. federal agencies
National Institute for Occupational Safety and Health (NIOSH) Criteria for a Recommended Standard, Occupational Exposure to Hexavalent Chromium NIOSH (2013) | - No MOA determined but acknowledges contribution from both mutagenic and cytotoxic MOAs.; - “Numerous studies report a broad spectrum of cellular responses induced by exposure to various Cr(VI) compounds. These cytotoxic and genotoxic responses are consistent with mechanistic events associated with carcinogenesis.”
Agency for Toxic Substances and Disease Registry (ATSDR) Toxicological Profile for Chromium ATSDR (2012) | - No MOA determined but acknowledges primary roles for cellular toxicity and genotoxicity.; - An analysis of genotoxicity evidence determined that “The vast majority of studies, therefore, clearly indicated that chromium (VI) compounds are genotoxic.”
Office of Pesticide Programs, U.S. EPA U.S. EPA (2008, 2009) | - Mutagenic MOA determined [see also (Mccarroll et al., 2010)]; - Independent MOA analysis uses EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a) and the draft Framework for Determining a Mutagenic MOA for Carcinogenicity (U.S. EPA, 2007) and concludes “Overall, the weight of evidence evaluation supports Cr(VI) acting through a mutagenic MOA. In addition, no data were found that an alternative MOA might be operative. Therefore, the Cancer Guidelines recommend a linear extrapolation for the oral exposure risk assessment.”
Occupational Safety and Health Administration (OSHA) Occupational Exposure to Hexavalent Chromium; Final Rule OSHA (2006b) | - A review of the evidence concludes a “genotoxic” MOA for cancer (no framework-based MOA analysis); - “After carefully considering all the epidemiological, animal and mechanistic evidence presented in the rulemaking record, OSHA regards all Cr(VI) compounds as agents able to induce carcinogenesis through a genotoxic mode of action.”
International agencies
World Health Organization (WHO), Chromium in drinking-water, Background document for development of WHO Guidelines for drinking-water quality WHO (2020) | - No MOA determined, but states that the evidence supports a “cytotoxic, threshold MOA.”; - Cites MOA analysis by Thompson et al. (2013) and evidence summarized by Health Canada (2016) and Moffat et al. (2018), concluding "Because of the uncertainties in the available data, the MOA cannot currently be definitively confirmed (EFSA, 2014; UK Committees, 2015; Health Canada, 2016). However, the overall weight of evidence supports a threshold MOA.”
Food Safety Commission of Japan (FSCJ) FSC (2019) | - Determined mechanism for Cr(VI)-induced small intestinal tumors in mice to be cytotoxicity leading to hyperplasia and tumorigenesis (no framework-based MOA analysis).; - Concluded lack of genotoxicity based on two studies: Aoki et al. (2019) (transgenic mouse duodenum) and Thompson et al. (2017) (transgenic rat duodenum): “On the basis of these results, FSCJ judged that the carcinogenic mechanism of Cr (VI) intakes through drinking water was hardly attributable to the genotoxicity.”; - No mechanism for rat oral tumors proposed.
Guidelines for Canadian Drinking Water Quality, Guideline Technical Document for Chromium, Health Canada Health Canada (2016) | - Cytotoxic MOA determined for intestinal tumors in mice [reviewed in (Moffat et al., 2018)].; - Cites MOA analysis by Thompson et al. (2013) that used the IPCS Framework for analyzing the human relevance of a cancer MOA (Meek et al., 2003; IPCS, 2007; Boobis et al., 2006) and adds “however, it should be noted that debates are still on-going on the MOA and appropriate model for chromium; current information relies primarily on work conducted by a single group of researchers (Thompson et al., 2013).”; - Concludes the weight of evidence supports a cytotoxic MOA and not a mutagenic MOA based primarily on “absence of mutagenicity in relevant tissues, and the absence of site concordance of mutagenicity and tumour development.”; - No MOA determined for rat oral tumors.
UK Committees on Toxicity, Mutagenicity, Carcinogenicity of Chemicals in Food, Consumer Products and the Environment COT (2015), chaired by Prof. Alan Boobis | - The Committee on Mutagenicity (COM) was specifically asked to consider whether the data in Thompson et al. (2014) and associated studies demonstrate a threshold for mutagenicity: “Overall the COM agreed that whilst the hypothesis was plausible, there were limited data to demonstrate a threshold for genotoxicity for Cr (VI) and was not convinced that there was a clear negative result for genotoxicity at low doses.”
European Commission, Scientific Committee Health and Environmental Risks (SCHER), Opinion on Chromium VI in toys EC (2015) | - Proposes a mutagenic MOA: “The weight of evidence supports the plausibility that chromium VI may act through a mutagenic and genotoxic mode of action (MOA)” (no framework-based MOA analysis).
European Food Safety Authority (EFSA) Panel on Contaminants in the Food Chain (CONTAM) EFSA CONTAM Panel (2014) | - Proposes two MOAs for cancer: (1) the formation of Cr(III)-DNA adducts and (2) DNA damage caused by ROS and oxidative stress, both leading to mutations (see Figure 17) (no framework-based MOA analysis).; - “The data available so far support that the reduction of Cr(VI) to Cr(III) along the gastrointestinal tract is efficient but it cannot be excluded that even at low dose levels a small percentage of Cr(VI) escapes gastrointestinal reduction to Cr(III). Once taken up in the cells, Cr(VI) is reduced to Cr(III) with formation of Cr-DNA adducts and production of oxidative stress (due to formation of reactive intermediates). Both modes of action can contribute to the genotoxicity and carcinogenicity of Cr(VI).”
World Health Organization (WHO), International Programme on Chemical Safety (IPCS), Concise International Chemical Assessment Document (CICAD) 78 IPCS (2013) | - Human relevance of animal tumors following oral exposures to Cr(VI) determined using the IPCS human relevance framework for cancer MOA (IPCS, 2007).; - No specific MOA determined but concludes “The findings of lung cancer after exposure to chromium (VI) are mainly from epidemiological studies, and thus the assessment of the mode of action for this endpoint is moot, and the mode of action analysis can concentrate on the oral cancer observed in rats and the intestinal cancer observed in mice (NTP, 2008). With regard to these cancers in rats and mice, there is evidence that genotoxic mechanisms may be involved in the mode of action, in which case there are no grounds for excluding human relevance on the basis of fundamental, qualitative differences in key events in the mode of action between experimental animals and humans.”; - A quantitative assessment for cancer risk from oral exposures was not conducted due to uncertainties in human and animal evidence.
World Health Organization (WHO), International Agency for Research on Cancer (IARC) IARC (2012) | - No MOA determined but concludes that “Several mechanisms are involved in the carcinogenesis induced by chromium (VI) that include the induction of DNA damage, the generation of oxidative stress and aneuploidy, leading to cell transformation.”
Dutch National Institute for Public Health and the Environment (RIVM) RIVM (2001) | - No MOA determined but concludes that “...the application of a threshold concept for genotoxicity/carcinogenicity of Cr(VI) compounds does not seem justified for any exposure route.”

MCL = maximum contaminant level; MRL = minimal risk level; PHG = public health goal.