# APPENDIX A SYSTEMATIC REVIEW PROTOCOL FOR HEXAVALENT CHROMIUM

The systematic review protocol for the IRIS Toxicological Assessment of Hexavalent Chromium, developed in 2019 prior to the current draft (U.S. EPA 2019b), has been updated to reflect refinements to the systematic review procedures implemented in this draft. The updated version can be found on the IRIS website: https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=343950.