# ABBREVIATIONS

ADAF: age-dependent adjustment factors
ADME: absorption, distribution, metabolism, and excretion
AIC: Akaike’s information criterion
ALT: alanine aminotransferase
ALP: alkaline phosphatase
Asc: ascorbate
AST: aspartate aminotransferase
ATSDR: Agency for Toxic Substances and Disease Registry
BAL: bronchoalveolar lavage
BALF: bronchoalveolar lavage fluid
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMI: body mass index
BMR: benchmark response
BMDC: bone marrow-derived stem cell
BW: body weight
CA: chromosomal aberration
CASRN: Chemical Abstracts Service Registry Number
CHO: Chinese hamster ovary (cell line cells)
CPHEA: Center for Public Health and Environmental Assessment
CL: confidence limit
CNS: central nervous system
Cr(III): trivalent chromium
Cr(IV): tetravalent chromium
Cr(V): pentavalent chromium
Cr(VI): hexavalent chromium
DAF: dosimetric adjustment factor
DLCO: diffusing capacity of carbon monoxide
DNA: deoxyribonucleic acid
ELF: epithelial lining fluid
EPA: Environmental Protection Agency
ER: extra risk
FDA: Food and Drug Administration
FEV1.0: forced expiratory volume of 1 second
FVC: forced vital capacity
GD: gestation day
GGT: γ-glutamyl transferase
GI: gastrointestinal
GLP: good laboratory practices
GSD: geometric standard deviation
GSH: glutathione
GST: glutathione-S-transferase
HAWC: Health Assessment Workspace Collaborative
Hgb: hemoglobin
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
8-OHdG: 8-hydroxy-2'-deoxyguanosine
i.p.: intraperitoneal
i.v.: intravenous
IRIS: Integrated Risk Information System
IUR: inhalation unit risk
LC_50_: median lethal concentration
LD_50_: median lethal dose
LDHicki: lactate dehydrogenase
LOAEL: lowest-observed-adverse-effect level
MCH: mean cell hemoglobin
MCHC: mean cell hemoglobin concentration
MCV: mean cell volume
MEF: maximal expiratory flow
MMAD: mas median aerodynamic diameter
MN: micronuclei
MOA: mode of action
MTD: maximum tolerated dose
CPHEA: Center for Public Health and Environmental Assessment
NIC: National Cancer Institute
NIOSH: National Institute for Occupational Safety and Health
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
ORD: Office of Research and Development
OSHA: Occupational Safety and Health Administration
PBPK: physiologically based pharmacokinetic
PCE: polychromatic erythrocytes
PDC: potassium dichromate
PECO: population, exposure, comparison, outcome
PFU: plaque-forming unit
PND: postnatal day
POD: point of departure
POD_[ADJ]_: duration-adjusted POD
POD_[HED]_: human equivalent dose POD
POD_[HEC]_: human equivalent concentration POD
RBC: red blood cell, also known as erythrocyte
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
RDDR: regional deposited dose ratio
RNA: ribonucleic acid
SCE: sister chromatid exchange
SD: standard deviation
SDH: sorbitol dehydrogenase
SE: standard error
SDD: sodium dichromate dihydrate
PK: pharmacokinetics
TSCATS: Toxic Substances Control Act Test Submissions
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
UF_D_: database uncertainty factor
WBS: white blood cells
WOS: Web of Science