# REFERENCES

Abramson, MJ; Perret, JL; Dharmage, SC; McDonald, VM; McDonald, CF. (2014). Distinguishing adult-onset asthma from COPD: a review and a new approach [Review]. Int J Chron Obstruct Pulmon Dis 9: 945–962. 10.2147/COPD.S46761.25246782
Abreu, M, d; Neto, AC; Carvalho, G; Casquillo, NV; Carvalho, N; Okuro, R; Ribeiro, GC; Machado, M; Cardozo, A; Silva, AS; Barboza, T; Vasconcellos, LR; Rodrigues, DA; Camilo, L; Carneiro, L; Jandre, F; Pino, AV; Giannella-Neto, A; Zin, WA; Corrêa, LH; Souza, MN; Carvalho, AR. (2016). Does acute exposure to aldehydes impair pulmonary function and structure? Respir Physiol Neurobiol 229: 34–42. 10.1016/j.resp.2016.04.002.27102012
Acheson, ED; Gardner, MJ; Pannett, B; Barnes, HR; Osmond, C; Taylor, CP. (1984). Formaldehyde in the British chemical industry: An occupational cohort study. Lancet 323: 611–616. 10.1016/S0140-6736(84)91007-9.
Aglan, MA; Mansour, GN. (2018). Hair straightening products and the risk of occupational formaldehyde exposure in hairstylists. Drug Chem Toxicol 43: 1–8. 10.1080/01480545.2018.1508215.30208742
Ahmed, S; Tsukahara, S; Tin-Tin-Win-Shwe; Yamamoto, S; Kunugita, N; Arashidani, K; Fujimaki, H. (2007). Effects of low-level formaldehyde exposure on synaptic plasticity-related gene expression in the hippocampus of immunized mice. J Neuroimmunol 186: 104–111. 10.1016/j.jneuroim.2007.03.010.17434604
Ai L, T. (2019). Endogenous formaldehyde is a memory-related molecule in mice and humans. 2: 446. 10.1038/s42003-019-0694-x.
Akbar-Khanzadeh, F; Vaquerano, MU; Akbar-Khanzadeh, M; Bisesi, MS. (1994). Formaldehyde exposure, acute pulmonary response, and exposure control options in a gross anatomy laboratory. Am J Ind Med 26: 61–75. 10.1002/ajim.4700260106.8074125
Albert, RE; Sellakumar, AR; Laskin, S; Kuschner, M; Nelson, N; Snyder, CA. (1982). Gaseous formaldehyde and hydrogen chloride induction of nasal cancer in the rat. J Natl Cancer Inst 68: 597–603.6951075
Alexandersson, R. (1988). Decreased lung function and exposure to formaldehyde in the wood working industry. A five-year follow-up. Arh Hig Rada Toksikol 39: 421–424.3273133
Alexandersson, R; Hedenstierna, G. (1988). Respiratory hazards associated with exposure to formaldehyde and solvents in acid-curing paints. Arch Environ Health 43: 222–227. 10.1080/00039896.1988.9934937.3260092
Alexandersson, R; Hedenstierna, G. (1989). Pulmonary function in wood workers exposed to formaldehyde: A prospective study. Arch Environ Health 44: 5–11. 10.1080/00039896.1989.9935865.2916856
Alexandersson, R; Hedenstierna, G; Kolmodin-Hedman, B. (1982). Exposure to formaldehyde: effects on pulmonary function. Arch Environ Health 37: 279–284. 10.1080/00039896.1982.10667579.7138077
Ames, BN; Gold, LS. (1990). Too many rodent carcinogens: mitogenesis increases mutagenesis [Review]. Science 249: 970–971. 10.1126/science.2136249.2136249
Amiri, A; Turner-Henson, A. (2017). The roles of formaldehyde exposure and oxidative stress in fetal growth in the second trimester. J Obstet Gynecol Neonatal Nurs 46: 51–62. 10.1016/j.jogn.2016.08.007.
Andersen, I. (1979). Formaldehyde in the indoor environment - health implications and the setting of standards. In PO Fanger; O Valbjorn (Eds.), Indoor climate: Effects on human comfort, performance, and health in residential, commercial, and light-industry buildings (pp. 65–87). Copenhagen, Denmark: Danish Building Research Institute.
Andersen, I; Molhave, L. (1983). Controlled human studies with formaldehyde. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 154–165). Washington, DC: Hemisphere Publishing.
Andersen, ME; Clewell, HJ; Bermudez, E; Dodd, DE; Willson, GA; Campbell, JL; Thomas, RS. (2010). Formaldehyde: integrating dosimetry, cytotoxicity, and genomics to understand dose-dependent transitions for an endogenous compound. Toxicol Sci 118: 716–731. 10.1093/toxsci/kfq303.20884683
Andersen, ME; Clewell, HJ, III; Bermudez, E; Willson, GA; Thomas, RS. (2008). Genomic signatures and dose-dependent transitions in nasal epithelial responses to inhaled formaldehyde in the rat. Toxicol Sci 105: 368–383. 10.1093/toxsci/kfn097.18499655
Anderson, GP. (2008). Endotyping asthma: new insights into key pathogenic mechanisms in a complex, heterogeneous disease. Lancet 372: 1107–1119. 10.1016/S0140-6736(08)61452-X.18805339
Andjelkovich, DA; Janszen, DB; Brown, MH; Richardson, RB; Miller, FJ. (1995). Mortality of iron foundry workers: IV. Analysis of a subcohort exposed to formaldehyde. J Occup Environ Med 37: 826–837. 10.1097/00043764-199507000-00012.7552467
Andrews, LS; Clary, JJ; Terrill, JB; Bolte, HF. (1987). Subchronic inhalation toxicity of methanol. J Toxicol Environ Health 20: 117–124. 10.1080/15287398709530965.3806698
Ankley, GT; Bennett, RS; Erickson, RJ; Hoff, DJ; Hornung, MW; Johnson, RD; Mount, DR; Nichols, JW; Russom, CL; Schmieder, PK; Serrrano, JA; Tietge, JE; Villeneuve, DL. (2010). Adverse outcome pathways: A conceptual framework to support ecotoxicology research and risk assessment [Review]. Environ Toxicol Chem 29: 730–741. 10.1002/etc.34.20821501
Annesi-Maesano, I; Hulin, M; Lavaud, F; Raherison, C; Kopferschmitt, C; de Blay, F; Charpin, DA; Denis, C. (2012). Poor air quality in classrooms related to asthma and rhinitis in primary schoolchildren of the French 6 Cities Study. Thorax 67: 682–688. 10.1136/thoraxjnl-2011-200391.22436169
Antelman, SM; Eichler, AJ; Black, CA; Kocan, D. (1980). Interchangeability of stress and amphetamine in sensitization. Science 207: 329–331. 10.1126/science.7188649.7188649
Apfelbach, R; Weiler, E. (1991). Sensitivity to odors in wistar rats is reduced after low-level formaldehyde-gas exposure. Naturwissenschaften 78: 221–223. 10.1007/bf01136085.1852218
Appelman, LM; Woutersen, RA; Zwart, A; Falke, HE; Feron, VJ. (1988). One-year inhalation toxicity study of formaldehyde in male rats with a damaged or undamaged nasal mucosa. J Appl Toxicol 8: 85–90. 10.1002/jat.2550080204.3379235
Arbes, SJ; Gergen, PJ; Elliott, L; Zeldin, DC. (2005). Prevalences of positive skin test responses to 10 common allergens in the US population: Results from the Third National Health and Nutrition Examination Survey. J Allergy Clin Immunol 116: 377–383. 10.1016/j.jaci.2005.05.017.16083793
Arican, RY; Sahin, Z; Ustunel, I; Sarikcioglu, L; Ozdem, S; Oguz, N. (2009). Effects of formaldehyde inhalation on the junctional proteins of nasal respiratory mucosa of rats. Exp Toxicol Pathol 61: 297–305. 10.1016/j.etp.2008.09.005.18996001
Armitage, JW; Cullis, CF. (1971). STUDIES OF REACTION BETWEEN NITROGEN-DIOXIDE AND SULFUR-DIOXIDE. Combust Flame 16: 125.
Armon, C. (2009). Smoking may be considered an established risk factor for sporadic ALS [Review]. Neurology 73: 1693–1698. 10.1212/WNL.0b013e3181c1df48.19917993
Armstrong, RW; Imrey, PB; Lye, MS; Armstrong, MJ; Yu, MC; Sani, S. (2000). Nasopharyngeal carcinoma in Malaysian Chinese: occupational exposures to particles, formaldehyde and heat. Int J Epidemiol 29: 991–998. 10.1093/ije/29.6.991.11101539
Asgharian, B; Price, OT; Schroeter, JD; Kimbell, JS; Singal, M. (2012). A lung dosimetry model of vapor uptake and tissue disposition. Inhal Toxicol 24: 182–193. 10.3109/08958378.2012.654857.22369194
Asher, MI; Keil, U; Anderson, HR; Beasley, R; Crane, J; Martinez, F; Mitchell, EA; Pearce, N; Sibbald, B; Stewart, AW. (1995). International Study of Asthma and Allergies in Childhood (ISAAC): rationale and methods. Eur Respir J 8: 483–491. 10.1183/09031936.95.08030483.7789502
Aslan, H; Songur, A; Tunc, AT; Ozen, OA; Bas, O; Yagmurca, M; Turgut, M; Sarsilmaz, M; Kaplan, S. (2006). Effects of formaldehyde exposure on granule cell number and volume of dentate gyrus: a histopathological and stereological study. Brain Res 1122: 191–200. 10.1016/j.brainres.2006.09.005.17011527
ATS (American Thoracic Society). (2000). What constitutes an adverse health effect of air pollution? Am J Respir Crit Care Med 161: 665–673. 10.1164/ajrccm.161.2.ats4-00.10673213
ATSDR (Agency for Toxic Substances and Disease Registry). (1999). Toxicological profile for formaldehyde [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp111.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2010). Addendum to the toxicological profile for formaldehyde. Atlanta, GA. http://www.atsdr.cdc.gov/toxprofiles/formaldehyde_addendum.pdf.
Attia, D; Mansour, N; Taha, F; El Dein, AS. (2014). Assessment of lipid peroxidation and p53 as a biomarker of carcinogenesis among workers exposed to formaldehyde in cosmetic industry. Toxicol Ind Health 32: 1097–1105. 10.1177/0748233714547152.25193344
Audrezet, MP; Robaszkiewicz, M; Mercier, B; Nousbaum, JB; Bail, JP; Hardy, E; Volant, A; Lozach, P; Charles, JF; Gouerou, H; Ferec, C. (1993). TP53 gene mutation profile in esophageal squamous-cell carcinomas. Cancer Res 53: 5745–5749.8242631
Axelsson, G. (1984). Selection bias in studies of spontaneous abortion among occupational groups. J Occup Med 26: 525–528.6611393
Axelsson, G; Lütz, C; Rylander, R. (1984). Exposure to solvents and outcome of pregnancy in university laboratory employees. Br J Ind Med 41: 305–312.6743577
Axelsson, G; Rylander, R. (1982). Exposure to anesthetic gases and spontaneous-abortion: Response bias in a postal questionnaire study. Int J Epidemiol 11: 250–256. 10.1093/ije/11.3.250.7129739
Aydın, S; Canpınar, H; Undeğer, U; Güç, D; Colakoğlu, M; Kars, A; Başaran, N. (2013). Assessment of immunotoxicity and genotoxicity in workers exposed to low concentrations of formaldehyde. Arch Toxicol 87: 145–153. 10.1007/s00204-012-0961-9.23100157
Aydin, S; Ogeturk, M; Kuloglu, T; Kavakli, A; Aydin, S. (2014). Effect of carnosine supplementation on apoptosis and irisin, total oxidant and antioxidants levels in the serum, liver and lung tissues in rats exposed to formaldehyde inhalation. Peptides 64C: 14–23. 10.1016/j.peptides.2014.11.008.
Bach, B; Pedersen, OF; Mølhave, L. (1990). Human performance during experimental formaldehyde exposure. Environ Int 16: 105–113. 10.1016/0160-4120(90)90150-5.
Bachand, AM; Mundt, KA; Mundt, DJ; Montgomery, RR. (2010). Epidemiological studies of formaldehyde exposure and risk of leukemia and nasopharyngeal cancer: A meta-analysis. Crit Rev Toxicol 40: 85–100. 10.3109/10408440903341696.20085478
Bahadori, K; Doyle-Waters, MM; Marra, C; Lynd, L; Alasaly, K; Swiston, J; Fitzgerald, JM. (2009). Economic burden of asthma: a systematic review [Review]. BMC Pulm Med 9: 24. 10.1186/1471-2466-9-24.19454036
Baird, DD; Wilcox, AJ; Weinberg, CR. (1986). Use of time to pregnancy to study environmental exposures. Am J Epidemiol 124: 470–480.3740046
Balkwill, FR; Capasso, M; Hagemann, T. (2012). The tumor microenvironment at a glance. J Cell Sci 125: 5591–5596. 10.1242/jcs.116392.23420197
Ballarin, C; Sarto, F; Giacomelli, L; Bartolucci, GB; Clonfero, E. (1992). Micronucleated cells in nasal mucosa of formaldehyde-exposed workers. Mutat Res Genet Toxicol 280: 1–7. 10.1016/0165-1218(92)90012-O.
Band, PR; Le, ND; Fang, R; Threlfall, WJ; Astrakianakis, G; Anderson, JT; Keefe, A; Krewski, D. (1997). Cohort mortality study of pulp and paper mill workers in British Columbia, Canada. Am J Epidemiol 146: 186–194. 10.1093/oxfordjournals.aje.a009250.9230781
Bansal, N; Uppal, V; Pathak, D. (2011). Toxic effect of formaldehyde on the respiratory organs of rabbits: a light and electron microscopic study. Toxicol Ind Health 27: 563–569. 10.1177/0748233710393398.21343228
Barnea, ER; Tal, J. (1991). Stress-related reproductive failure [Review]. 8: 15–23. 10.1007/bf01131586.
Barnes, PJ. (2008). Immunology of asthma and chronic obstructive pulmonary disease [Review]. Nat Rev Immunol 8: 183–192. 10.1038/nri2254.18274560
Barrow, CS; Steinhagen, WH; Chang, JCF. (1983). Formaldehyde sensory irritation. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 16–25). Washington, DC: Hemisphere Publishing.
Barton, HA; Chiu, WA; Setzer, RW; Andersen, ME; Bailer, AJ; Bois, FY; Dewoskin, RS; Hays, S; Johanson, G; Jones, N; Loizou, G; Macphail, RC; Portier, CJ; Spendiff, M; Tan, YM. (2007). Characterizing uncertainty and variability in physiologically-based pharmacokinetic (PBPK) models: State of the science and needs for research and implementation. Toxicol Sci 99: 395–402. 10.1093/toxsci/kfm100.17483121
Bassig, B; Zhang, L; Cawthon, R; Yin, S; Li, G; Rappaport, S; Hu, W, ei; Smith, MT; Rothman, N; Vermeulen, R; Lan, Q. (2012). Occupational exposure to benzene and leukocyte telomere length. Cancer Res 72. 10.1158/1538-7445.AM2012-4474.
Bassig, BA; Zhang, L; Vermeulen, R; Tang, X; Li, G; Hu, W, ei; Guo, W; Purdue, MP; Yin, S; Rappaport, SM; Shen, M, in; Ji, Z; Qiu, C; Ge, Y; Hosgood, HD; Reiss, B; Wu, B; Xie, Y; Li, L; Yue, F, ei; Freeman, LEB; Blair, A; Hayes, RB; Huang, H; Smith, MT; Rothman, N; Lan, Q. (2016). Comparison of hematological alterations and markers of B-cell activation in workers exposed to benzene, formaldehyde and trichloroethylene. Carcinogenesis 37: 692–700. 10.1093/carcin/bgw053.27207665
Bates, JH; Rincon, M; Irvin, CG. (2009). Animal models of asthma [Review]. Am J Physiol Lung Cell Mol Physiol 297: L401–L410. 10.1152/ajplung.00027.2009.19561139
Bates, JHT; Irvin, CG. (2003). Measuring lung function in mice: the phenotyping uncertainty principle. J Appl Physiol (1985) 94: 1297–1306. 10.1152/japplphysiol.00706.2002.12626466
Bateson, TF; Schwartz, J. (2008). Children’s response to air pollutants [Review]. J Toxicol Environ Health A 71: 238–243. 10.1080/15287390701598234.18097949
Battelle (Battelle Columbus Laboratories). (1981). Final report on a chronic inhalation toxicology study in rats and mice exposed to formaldehyde to Chemical Industry Institute of Toxicology: Volume 1. Research Triangle Park, NC: Chemical Industry Institute of Toxicology.
Battelle (Battelle Columbus Laboratories). (1982). A chronic inhalation toxicology study in rats and mice exposed to formaldehyde. Research Triangle Park, NC: Chemical Industry Institute of Toxicology. http://al-pdf://CIIT 1982 FA1340 Vol1A_OCR-2178554371/CIIT 1982 FA1340 Vol1A_OCR.pdf.
Bautista, DM; Jordt, SE; Nikai, T; Tsuruda, PR; Read, AJ; Poblete, J; Yamoah, EN; Basbaum, AI; Julius, D. (2006). TRPA1 Mediates the Inflammatory Actions of Environmental Irritants and Proalgesic Agents. Cell 124: 1269–1282. 10.1016/j.cell.2006.02.023.16564016
Beane Freeman, LE; Blair, A; Lubin, JH; Stewart, PA; Hayes, RB; Hoover, RN; Hauptmann, M. (2013). Mortality from solid tumors among workers in formaldehyde industries: an update of the NCI cohort. Am J Ind Med 56: 1015–1026. 10.1002/ajim.22214.23788167
Beane Freeman, LE; Blair, A; Lubin, JH; Stewart, PA; Hayes, RB; Hoover, RN; M, H. (2009). Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries: The National Cancer Institute Cohort. J Natl Cancer Inst 101: 751–761. 10.1093/jnci/djp096.19436030
Becklake, MR; White, N. (1993). Sources of variation in spirometric measurements. Identifying the signal and dealing with noise [Review]. Occup Med 8: 241–264.8506504
Beland, FA; Fullerton, NF; Heflich, RH. (1984). Rapid isolation, hydrolysis and chromatography of formaldehyde-modified DNA. J Chromatogr A 308: 121–131. 10.1016/0378-4347(84)80202-9.
Bell, IR; Baldwin, CM; Fernandez, M; Schwartz, GE. (1999). Neural sensitization model for multiple chemical sensitivity: overview of theory and empirical evidence [Review]. Toxicol Ind Health 15: 295–304. 10.1177/074823379901500303.10416281
Bell, IR; Miller, CS; Schwartz, GE. (1992). An olfactory-limbic model of multiple chemical sensitivity syndrome: Possible relationships to kindling and affective spectrum disorders [Review]. Biol Psychiatry 32: 218–242. 10.1016/0006-3223(92)90105-9.1420641
Bellavia, A; Dickerson, AS; Rotem, RS; Hansen, J; Gredal, O; Weisskopf, MG. (2021). Joint and interactive effects between health comorbidities and environmental exposures in predicting amyotrophic lateral sclerosis. Int J Hyg Environ Health 231: 113655. 10.1016/j.ijheh.2020.113655.33130429
Bellisario, V; Mengozzi, G; Grignani, E; Bugiani, M; Sapino, A; Bussolati, G; Bono, R. (2016). Towards a formalin-free hospital. Levels of 15-F2t-isoprostane and malondialdehyde to monitor exposure to formaldehyde in nurses from operating theatres. Toxicology Research 5: 1122–1129. 10.1039/c6tx00068a.30090418
Bender, JR; Mullin, LS; Grapel, GJ; Wilson, WE. (1983). Eye irritation response of humans to formaldehyde. Am Ind Hyg Assoc J 44: 463–465. 10.1080/15298668391405139.6881068
Benedetti, MS; Whomsley, R; Canning, M. (2007). Drug metabolism in the paediatric population and in the elderly [Review]. Drug Discov Today 12: 599–610. 10.1016/j.drudis.2007.06.011.17706541
Bentayeb, M; Norback, D; Bednarek, M; Bernard, A; Cai, G; Cerrai, S; Eleftheriou, KK; Gratziou, C; Holst, GJ; Lavaud, F; Nasilowski, J; Sestini, P; Sarno, G; Sigsgaard, T; Wieslander, G; Zielinski, J; Viegi, G; Annesi-Maesano, I; Study, G. (2015). Indoor air quality, ventilation and respiratory health in elderly residents living in nursing homes in Europe. Eur Respir J 45: 1228–1238. 10.1183/09031936.00082414.25766977
Berglund, B; Höglund, A; Esfandabad, HS. (2012). A bisensory method for odor and irritation detection of formaldehyde and pyridine. Chemosensory Perception 5: 146–157. 10.1007/s12078-011-9101-9.
Berglund, B; Nordin, S. (1992). Detectability and perceived intensity for formaldehyde in smokers and non-smokers. Chem Senses 17: 291–306. 10.1093/chemse/17.3.291.
Berke, JH. (1987). Cytologic examination of the nasal mucosa in formaldehyde-exposed workers. J Occup Environ Med 29: 681–684.
Bermudez, EG. (2004). HCHO studies - Tumor incidence [Memorandum].
Berrino, F; Richiardi, L; Boffetta, P; Estève, J; Belletti, I; Raymond, L; Troschel, L; Pisani, P; Zubiri, L; Ascunce, N; Gubéran, E; Tuyns, A; Terracini, B; Merletti, F; Group, MJW. (2003). Occupation and larynx and hypopharynx cancer: A job-exposure matrix approach in an international case-control study in France, Italy, Spain and Switzerland. Cancer Causes Control 14: 213–223. 10.1023/a:1023661206177.12814200
Bertazzi, PA; Pesatori, AC; Radice, L; Zocchetti, C. (1986). Exposure to formaldehyde and cancer mortality in a cohort of workers producing resins. Scand J Work Environ Health 12: 461–468. doi:10.5271/sjweh.2111.3787218
Bhalla, DK; Mahavni, V; Nguyen, T; Mcclure, T. (1991). Effects of acute exposure to formaldehyde on surface morphology of nasal epithelia in rats. J Toxicol Environ Health 33: 171–188. 10.1080/15287399109531516.2051493
Biagini, RE; Moorman, WJ; Knecht, EA; Clark, JC; Bernstein, IL. (1989). Acute airway narrowing in monkeys from challenge with 2.5 ppm formaldehyde generated from formalin. Arch Environ Health 44: 12–17. 10.1080/00039896.1989.9935866.2644895
Bian, RX; Han, JY; Kim, JK; Choi, IS; Lee, SG; Park, JS; Jung, YD. (2012). The effect of chronic formaldehyde exposure on the hippocampus in chronic cerebral hypoperfusion rat model. Toxicol Environ Chem 94: 1211–1224. 10.1080/02772248.2012.691505.
Billionnet, C; Gay, E; Kirchner, S; Leynaert, B; Annesi-Maesano, I. (2011). Quantitative assessments of indoor air pollution and respiratory health in a population-based sample of French dwellings. Environ Res 111: 425–434. 10.1016/j.envres.2011.02.008.21397225
Blair, A; Saracci, R; Stewart, PA; Hayes, RB; Shy, C. (1990). Epidemiologic evidence on the relationship between formaldehyde exposure and cancer [Review]. Scand J Work Environ Health 16: 381–393. 10.5271/sjweh.1767.2284588
Blair, A; Stewart, P; O’Berg, M; Gaffey, W; Walrath, J; Ward, J; Bales, R; Kaplan, S; Cubit, D. (1986). Mortality among industrial workers exposed to formaldehyde. J Natl Cancer Inst 76: 1071–1084.3458945
Blair, A; Zheng, T; Linos, A; Stewart, PA; Zhang, YW; Cantor, KP. (2001). Occupation and leukemia: A population-based case-control study in Iowa and Minnesota. Am J Ind Med 40: 3–14. 10.1002/ajim.1066.11439392
Boffetta, P; Stellman, SD; Garfinkel, L. (1989). A case-control study of multiple myeloma nested in the American Cancer Society prospective study. Int J Cancer 43: 554–559. 10.1002/ijc.2910430404.2703267
Bogdanffy, MS; Morgan, PH; Starr, TB; Morgan, KT. (1987). Binding of formaldehyde to human and rat nasal mucus and bovine serum albumin. Toxicol Lett 38: 145–154. 10.1016/0378-4274(87)90122-6.3629625
Bogdanffy, MS; Randall, HW; Morgan, KT. (1986). Histochemical localization of aldehyde dehydrogenase in the respiratory tract of the Fischer-344 rat. Toxicol Appl Pharmacol 82: 560–567. 10.1016/0041-008X(86)90291-7.3952738
Bogdanffy, MS; Sarangapani, R; Plowchalk, DR; Jarabek, AM; Andersen, ME. (1999). A biologically based risk assessment for vinyl acetate-induced cancer and noncancer inhalation toxicity. Toxicol Sci 51: 19–35. 10.1093/toxsci/51.1.19.10496674
Boja, JW; Nielsen, JA; Foldvary, E; Truitt, EB, Jr. (1985). Acute low-level formaldehyde behavioural and neurochemical toxicity in the rat. Prog Neuropsychopharmacol Biol Psychiatry 9: 671–674. 10.1016/0278-5846(85)90038-7.4089191
Bokina, AI; Eksler, ND; Semenenko, AD; Merkur’yeva, RV. (1976). Investigation of the mechanism of action of atmospheric pollutants on the central nervous system and comparative evaluation of methods of study. Environ Health Perspect 13: 37–42. 10.2307/3428235.1269506
Bolm-Audorff, U; Vogel, C; Woitowitz, H. (1990). Occupation and smoking as risk factors of nasal and nasopharyngeal cancer. In RR Monson (Ed.), Occupational epidemiology (2nd ed., pp. 71–74). Boca Raton, FL: CRC Press.
Bonassi, S; El-Zein, R; Bolognesi, C; Fenech, M. (2011). Micronuclei frequency in peripheral blood lymphocytes and cancer risk: evidence from human studies [Review]. Mutagenesis 26: 93–100. 10.1093/mutage/geq075.21164188
Bonassi, S; Lando, C; Ceppi, M; Landi, S; Rossi, AM; Barale, R. (2004a). No association between increased levels of high-frequency sister chromatid exchange cells (HFCs) and the risk of cancer in healthy individuals. Environ Mol Mutagen 43: 134–136. 10.1002/em.20006.14991754
Bonassi, S; Norppa, H; Ceppi, M; Stromberg, U; Vermeulen, R; Znaor, A; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Gundy, S; Hansteen, IL; Knudsen, LE; Lazutka, J; Rossner, P; Sram, RJ; Boffetta, P. (2008). Chromosomal aberration frequency in lymphocytes predicts the risk of cancer: results from a pooled cohort study of 22 358 subjects in 11 countries. Carcinogenesis 29: 1178–1183. 10.1093/carcin/bgn075.18356148
Bonassi, S; Ugolini, D; Kirsch-Volders, M; Strömberg, U; Vermeulen, R; Tucker, JD. (2005). Human population studies with cytogenetic biomarkers: review of the literature and future prospectives [Review]. Environ Mol Mutagen 45: 258–270. 10.1002/em.20115.15688363
Bonassi, S; Znaor, A; Ceppi, M; Lando, C; Chang, WP; Holland, N; Kirsch-Volders, M; Zeiger, E; Ban, S; Barale, R; Bigatti, MP; Bolognesi, C; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Hagmar, L; Joksic, G; Martelli, A; Migliore, L; Mirkova, E; Scarfi, MR; Zijno, A; Norppa, H; Fenech, M. (2007). An increased micronucleus frequency in peripheral blood lymphocytes predicts the risk of cancer in humans. Carcinogenesis 28: 625–631. 10.1093/carcin/bgl177.16973674
Bonassi, S; Znaor, A; Norppa, H; Hagmar, L. (2004b). Chromosomal aberrations and risk of cancer in humans: an epidemiologic perspective [Review]. Cytogenet Genome Res 104: 376–382. 10.1159/000077519.15162068
Bono, R; Munnia, A; Romanazzi, V; Bellisario, V; Cellai, F; Peluso, MEM. (2016). Formaldehyde-induced toxicity in the nasal epithelia of workers of a plastic laminate plant. Toxicology Research 5: 752–760. 10.1039/c5tx00478k.30090386
Bono, R; Romanazzi, V; Munnia, A; Piro, S; Allione, A; Ricceri, F; Guarrera, S; Pignata, C; Matullo, G; Wang, P; Giese, RW; Peluso, M. (2010). Malondialdehyde-deoxyguanosine adduct formation in workers of pathology wards: the role of air formaldehyde exposure. Chem Res Toxicol 23: 1342–1348. 10.1021/tx100083x.20707408
Bono, R; Romanazzi, V; Pirro, V; Degan, R; Pignata, C; Suppo, E; Pazzi, M; Vincenti, M. (2012). Formaldehyde and tobacco smoke as alkylating agents: The formation of N-methylenvaline in pathologists and in plastic laminate workers. Sci Total Environ 414: 701–707. 10.1016/j.scitotenv.2011.10.047.22104379
Boreiko, CJ; Ragan, DL. (1983). Formaldehyde effects in the C3H/10T½ cell transformation assay. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 63–71). Washington, DC: Hemisphere Publishing Corporation.
Bosetti, C; Mclaughlin, JK; Tarone, RE; Pira, E; La Vecchia, C. (2008). Formaldehyde and cancer risk: a quantitative review of cohort studies through 2006 [Review]. Ann Oncol 19: 29–43. 10.1093/annonc/mdm202.17897961
Bowen, SE; Hannigan, JH. (2006). Developmental toxicity of prenatal exposure to toluene [Review]. AAPS J 8: E419–E424. 10.1007/BF02854915.16808045
Boysen, M; Zadig, E; Digernes, V; Abeler, V; Reith, A. (1990). Nasal mucosa in workers exposed to formaldehyde: a pilot study. Occup Environ Med 47: 116–121. 10.1136/oem.47.2.116.
Bracken, MJ; Leasa, DJ; Morgan, WKC. (1985). Exposure to formaldehyde: Relationship to respiratory symptoms and function. Can J Public Health 76: 312–316.4084884
Branco, PTB; Alvim-Ferraz, MCM; Martins, FG; Ferraz, C; Vaz, LG; Sousa, SIV. (2020). Impact of indoor air pollution in nursery and primary schools on childhood asthma. Sci Total Environ 745: 140982. 10.1016/j.scitotenv.2020.140982.32736106
Branzei, D; Foiani, M. (2008). Regulation of DNA repair throughout the cell cycle [Review]. Nat Rev Mol Cell Biol 9: 297–308. 10.1038/nrm2351.18285803
Braun-Fahrländer, C; Wüthrich, B; Gassner, M; Grize, L; Sennhauser, FH; Varonier, HS; Vuille, JC. (1997). Validation of a rhinitis symptom questionnaire (ISAAC core questions) in a population of Swiss school children visiting the school health services. Pediatric Allergy and Immunology 8: 75–82. 10.1111/j.1399-3038.1997.tb00147.x.9617776
Breysse, PA. (1984). Formaldehyde levels and accompanying symptoms associated with individuals residing in over 1000 conventional and mobile homes in the state of Washington. In B Berglund; T Lindvall; J Sundell (Eds.), Indoor air: Proceedings of the 3rd International Conference on Indoor Air Quality and Climate Volume 3: Sensory and hyperreactivity reactions to sick buildings (pp. 403–408). Stockholm, Sweden: Swedish Council for Building Research. https://search.proquest.com/docview/14197938?accountid=171501.
Brinton, LA; Blot, WJ; Becker, JA; Winn, DM; Browder, JP; Farmer, JC, Jr; Fraumeni, JF, Jr. (1984). A case-control study of cancers of the nasal cavity and paranasal sinuses. Am J Epidemiol 119: 896–906. 10.1093/oxfordjournals.aje.a113812.6731431
Brinton, LA; Blot, WJ; Fraumeni, JF, Jr. (1985). Nasal cancer in the textile and clothing industries. Occup Environ Med 42: 469–474.
Broadhurst, PL. (1969). Psychogenetics of emotionality in the rat. Ann N Y Acad Sci 159: 806–824. 10.1111/j.1749-6632.1969.tb12980.x.5260300
Broder, I; Corey, P; Brasher, P; Lipa, M; Cole, P. (1988a). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: III. Health and house variables following remedial work. Environ Res 45: 179–203. 10.1016/S0013-9351(88)80046-X.3349974
Broder, I; Corey, P; Cole, P; Lipa, M; Mintz, S; Nethercott, JR. (1988b). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: I Methodology. Environ Res 45: 141–155. 10.1016/S0013-9351(88)80044-6.3349973
Broder, I; Corey, P; Cole, P; Lipa, M; Mintz, S; Nethercott, JR. (1988c). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: II initial health and house variables and exposure-response relationships. Environ Res 45: 156–178. 10.1016/S0013-9351(88)80045-8.3127198
Brondeau, MT; Bonnet, P; Guenier, JP; Simon, P; de Ceaurriz, J. (1990). Adrenal-dependent leucopenia after short-term exposure to various airborne irritants in rats. J Appl Toxicol 10: 83–86. 10.1002/jat.2550100204.2362083
Brooks, BR. (1994). El Escorial World Federation of Neurology criteria for the diagnosis of amyotrophic lateral sclerosis. J Neurol Sci 124: 96–107. 10.1016/0022-510X(94)90191-0.7807156
Brooks, PJ; Zakhari, S. (2014). Acetaldehyde and the genome: Beyond nuclear DNA adducts and carcinogenesis [Review]. Environ Mol Mutagen 55: 77–91. 10.1002/em.21824.24282063
Brown, HR. (1990). Neoplastic and Potentially Preneoplastic Changes in the Upper Respiratory Tract of Rats and Mice. Environ Health Perspect 85: 291. 10.2307/3430690.2384063
Brown, HR; Monticello, TM; Maronpot, RR; Randall, HW; Hotchkiss, JR; Morgan, KT. (1991). Proliferative and neoplastic lesions in the rodent nasal cavity. Toxicol Pathol 19: 358–372. 10.1177/0192623391019004-105.1813982
Buckley, LA; Jiang, XZ; James, RA; Morgan, KT; Barrow, CS. (1984). Respiratory tract lesions induced by sensory irritants at the RD50 concentration. Toxicol Appl Pharmacol 74: 417–429. 10.1016/0041-008X(84)90295-3.6740688
Buckley, LA; Morgan, KT; Swenberg, JA; James, RA; Jr, H T; Barrow, CS. (1985). The toxicity of dimethylamine in F-344 rats and B6C3F1 mice following a 1-year inhalation exposure. Fundam Appl Toxicol 5: 341–352. 10.1093/toxsci/5.2.341.3988003
Buckley, TM; Schatzberg, AF. (2005). On the interactions of the hypothalamic-pituitary-adrenal (HPA) axis and sleep: normal HPA axis activity and circadian rhythm, exemplary sleep disorders [Review]. J Clin Endocrinol Metab 90: 3106–3114. 10.1210/jc.2004-1056.15728214
Burgaz, S; Cakmak, G; Erdem, O; Yilmaz, M; Karakaya, AE. (2001). Micronuclei frequencies in exfoliated nasal mucosa cells from pathology and anatomy laboratory workers exposed to formaldehyde. Neoplasma 48: 144–147.11478696
Burgaz, S; Erdem, O; Cakmak, G; Erdem, N; Karakaya, A; Karakaya, AE. (2002). Cytogenetic analysis of buccal cells from shoe-workers and pathology and anatomy laboratory workers exposed to n-hexane, toluene, methyl ethyl ketone and formaldehyde. Biomarkers 7: 151–161. 10.1080/13547500110113242.12101634
Burgos-Barragan, G; Wit, N; Meiser, J; Dingler, FA; Pietzke, M; Mulderrig, L; Pontel, LB; Rosado, IV; Brewer, TF; Cordell, RL; Monks, PS; Chang, CJ; Vazquez, A; Patel, KJ. (2017a). Erratum: Mammals divert endogenous genotoxic formaldehyde into one-carbon metabolism [Erratum]. Nature 548: 612. 10.1038/nature23904.
Burgos-Barragan, G; Wit, N; Meiser, J; Dingler, FA; Pietzke, M; Mulderrig, L; Pontel, LB; Rosado, IV; Brewer, TF; Cordell, RL; Monks, PS; Chang, CJ; Vazquez, A; Patel, KJ. (2017b). Mammals divert endogenous genotoxic formaldehyde into one-carbon metabolism. Nature 548: 549–554. 10.1038/nature23481.28813411
Burney, PG; Laitinen, LA; Perdrizet, S; Huckauf, H; Tattersfield, AE; Chinn, S; Poisson, N; Heeren, A; Britton, JR; Jones, T. (1989). Validity and repeatability of the IUATLD (1984) Bronchial Symptoms Questionnaire: an international comparison. Eur Respir J 2: 940–945.2606194
Cadieux, A; Springall, DR; Mulderry, PK; Rodrigo, J; Ghatei, MA; Terenghi, G; Bloom, SR; Polak, JM. (1986). Occurrence, distribution and ontogeny of CGRP immunoreactivity in the rat lower respiratory tract: effect of capsaicin treatment and surgical denervations. Neuroscience 19: 605–627.3490633
Callas, PW; Pastides, H; Hosmer, DW. (1998). Empirical comparisons of proportional hazards, poisson, and logistic regression modeling of occupational cohort data. Am J Ind Med 33: 33–47. 10.1002/(sici)1097-0274(199801)33:1<33::aid-ajim5>3.0.co;2-x.9408527
Campbell Jr, JL; Gentry, PR; Clewell III, HJ; Andersen, ME. (2020). A kinetic analysis of DNA-deoxy guanine adducts in the nasal epithelium produced by inhaled formaldehyde in rats-assessing contributions to adduct production from both endogenous and exogenous sources of formaldehyde. Toxicol Sci 177: 325–333. 10.1093/toxsci/kfaa122.32735340
Carr, MJ; Undem, BJ. (2001). Inflammation-induced plasticity of the afferent innervation of the airways. Environ Health Perspect 4: 567–571.
Casanova-Schmitz, M; David, RM; Heck, H. (1984a). Oxidation of formaldehyde and acetaldehyde by NAD+-dependent dehydrogenases in rat nasal mucosal homogenates. Biochem Pharmacol 33: 1137–1142. 10.1016/0006-2952(84)90526-4.6477684
Casanova-Schmitz, M; Heck, H. (1983). Effects of formaldehyde exposure on the extractability of DNA from proteins in the rat nasal mucosa. Toxicol Appl Pharmacol 70: 121–132. 10.1016/0041-008x(83)90185-0.6193611
Casanova-Schmitz, M; Starr, TB; Heck, HD. (1984b). Differentiation between metabolic incorporation and covalent binding in the labeling of macromolecules in the rat nasal mucosa and bone marrow by inhaled [14C]- and [3H]formaldehyde. Toxicol Appl Pharmacol 76: 26–44. 10.1016/0041-008x(84)90026-7.6207627
Casanova, M; Deyo, DF; Heck, H. (1989). Covalent binding of inhaled formaldehyde to DNA in the nasal mucosa of Fischer 344 rats: Analysis of formaldehyde and DNA by high-performance liquid chromatography and provisional pharmacokinetic interpretation. Fundam Appl Toxicol 12: 397–417. 10.1016/0272-0590(89)90015-8.2731656
Casanova, M; Heck, H. (1987). Further studies of the metabolic incorporation and covalent binding of inhaled [3H]- and [14C]formaldehyde in Fischer-344 rats: Effects of glutathione depletion. Toxicol Appl Pharmacol 89: 105–121. 10.1016/0041-008X(87)90181-5.2438809
Casanova, M; Heck, H. (1997). Lack of evidence for the involvement of formaldehyde in the hepatocarcinogenicity of methyl tertiary-butyl ether in CD-1 mice. Chem Biol Interact 105: 131–143.9251725
Casanova, M; Heck, H; Everitt, JI; Harrington, WW, Jr; Popp, JA. (1988). Formaldehyde concentrations in the blood of rhesus monkeys after inhalation exposure. Food Chem Toxicol 26: 715–716. 10.1016/0278-6915(88)90071-3.3198038
Casanova, M; Morgan, KT; Gross, EA; Moss, OR; Heck, H. (1994). DNA-protein cross-links and cell replication at specific sites in the nose of F344 rats exposed subchronically to formaldehyde. Fundam Appl Toxicol 23: 525–536. 10.1006/faat.1994.1137.7867904
Casanova, M; Morgan, KT; Steinhagen, WH; Everitt, JI; Popp, JA; Heck, H. (1991). Covalent binding of inhaled formaldehyde to DNA in the respiratory tract of rhesus monkeys: pharmacokinetics, rat-to-monkey interspecies scaling, and extrapolation to man. Toxicol Sci 17: 409–428. 10.1016/0272-0590(91)90230-2.
Cassee, FR; Feron, VJ. (1994). Biochemical and histopathological changes in nasal epithelium of rats after 3-day intermittent exposure to formaldehyde and ozone alone or in combination. Toxicol Lett 72: 257–268. 10.1016/0378-4274(94)90037-x.7911263
Cassee, FR; Groten, JP; Feron, VJ. (1996). Changes in the nasal epithelium of rats exposed by inhalation to mixtures of formaldehyde, acetaldehyde, and acrolein. Toxicol Sci 29: 208–218. 10.1006/faat.1996.0024.
Casset, A; Marchand, C; Purohit, A; le Calve, S; Uring-Lambert, B; Donnay, C; Meyer, P; de Blay, F. (2006). Inhaled formaldehyde exposure: effect on bronchial response to mite allergen in sensitized asthma patients. Allergy 61: 1344–1350. 10.1111/j.1398-9995.2006.01174.x.17002712
Casset, A; Purohit, A; Marchand, C; Le Calve, S; Pauli, G; de Blay, F. (2007). Inhaled formaldehyde and the bronchial response. Rev Fr Allergol Immunol Clin 47: 80–83. 10.1016/j.allerg.2006.10.009.
CDC (Centers for Disease Control and Prevention). (2004). The health consequences of smoking: A report of the Surgeon General. Washington, DC: U.S. Department of Health and Human Services. http://www.cdc.gov/tobacco/data_statistics/sgr/2004/index.htm.
Ceppi, M; Biasotti, B; Fenech, M; Bonassi, S. (2010). Human population studies with the exfoliated buccal micronucleus assay: Statistical and epidemiological issues [Review]. Mutat Res Rev Mutat Res 705: 11–19. 10.1016/j.mrrev.2009.11.001.
Chamanza, R; Wright, JA. (2015). A review of the comparative anatomy, histology, physiology and pathology of the nasal cavity of rats, mice, dogs and non-human primates. Relevance to inhalation toxicology and human health risk assessment [Review]. J Comp Pathol 153: 287–314. 10.1016/j.jcpa.2015.08.009.26460093
Chan-Yeung, M. (2000). Spirometry and tests of bronchial hyperresponsiveness in population studies [Review]. Int J Tuberc Lung Dis 4: 633–638.10907766
Chandra, M; Riley, MG; Johnson, DE. (1992). Spontaneous neoplasms in aged Sprague-Dawley rats. Arch Toxicol 66: 496–502. 10.1007/BF01970675.1444814
Chang, JCF; Barrow, CS. (1984). Sensory irritation tolerance and cross-tolerance in F-344 rats exposed to chlorine or formaldehyde gas. Toxicol Appl Pharmacol 76: 319–327. 10.1016/0041-008X(84)90013-9.6495337
Chang, JCF; Gross, EA; Swenberg, JA; Barrow, CS. (1983). Nasal cavity deposition, histopathology, and cell proliferation after single or repeated formaldehyde exposures in B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 68: 161–176. 10.1016/0041-008x(83)90001-7.6857658
Chang, JCF; Steinhagen, WH; Barrow, CS. (1981). Effect of single or repeated formaldehyde exposure on minute volume of B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 61: 451–459. 10.1016/0041-008x(81)90368-9.7330883
Chang, M; Park, H; Ha, M; Hong, YC; Lim, YH; Kim, Y; Kim, YJ; Lee, D; Ha, EH. (2017). The effect of prenatal TVOC exposure on birth and infantile weight: the Mothers and Children’s Environmental Health study. Pediatr Res 82: 423–428. 10.1038/pr.2017.55.28422943
Checkoway, H; Dell, LD; Boffetta, P; Gallagher, AE; Crawford, L; Lees, PS; Mundt, KA. (2015). Formaldehyde Exposure and Mortality Risks From Acute Myeloid Leukemia and Other Lymphohematopoietic Malignancies in the US National Cancer Institute Cohort Study of Workers in Formaldehyde Industries. J Occup Environ Med 57: 785–794. 10.1097/JOM.0000000000000466.26147546
Chen, CJ; You, SL; Lin, LH; Hsu, WL; Yang, YW. (2002). Cancer epidemiology and control in Taiwan: A brief review. Jpn J Clin Oncol 32: S66–S81. 10.1093/jjco/hye138.11959880
Cheng, G; Wang, M; Upadhyaya, P; Villalta, PW; Hecht, SS. (2008). Formation of formaldehyde adducts in the reactions of DNA and deoxyribonucleosides with alpha-acetates of 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone (NNK), 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol (NNAL), and N-nitrosodimethylamine (NDMA). Chem Res Toxicol 21: 746–751. 10.1021/tx7003823.18205321
Cheng, YJ; Hildesheim, A; Hsu, MM; Chen, IH; Brinton, LA; Levine, PH; Chen, CJ; Yang, CS. (1999). Cigarette smoking, alcohol consumption and risk of nasopharyngeal carcinoma in Taiwan. Cancer Causes Control 10: 201–207. 10.1023/A:1008893109257.10454065
Cheng, Z; Li, Y; Liang, B; Wang, C. (2004). [Investigation of formaldehyde level and health of personnel in clinical pathology]. 29: 266–267.
Cho, S; Kim, HJ; Oh, SH; Park, CO; Jung, JY; Lee, KH. (2010). The influence of pregnancy and menstruation on the deterioration of atopic dermatitis symptoms. Annals of Dermatology 22: 180–185. 10.5021/ad.2010.22.2.180.20548909
Choi, DW; Moon, KW; Byeon, SH; Lee, EI; Sul, DG; Lee, JH; Oh, EH; Kim, YH. (2009). Indoor volatile organic compounds in atopy patients’ houses in South Korea. Indoor Built Environ 18: 144–154. 10.1177/1420326X08101945.
Chonglei, L; Fan, W; Wei, L; Yihe, J. (2012). Effects of Exposure to VOCs on Spatial Learning and Memory Capacity and the Expression of NMDA Receptor in Mice. Journal of Animal and Veterinary Advances 11: 3355–3364.
CIIT (Chemical Industry Institute of Toxicology). (1999). Formaldehyde: hazard characterization and dose-response assessment for carcinogenicity by the route of inhalation.
Clarisse, B; Laurent, AM; Seta, N; Le Moullec, Y; El Hasnaoui, A; Momas, I. (2003). Indoor aldehydes: measurement of contamination levels and identification of their determinants in Paris dwellings. Environ Res 92: 245–253. 10.1016/S0013-9351(03)00039-2.12804521
Clayton, TC; Meade, TW; Turner, EL; De Stavola, BL. (2014). Peak flow rate and death due to coronary heart disease: 30-year results from the Northwick Park Heart cohort study. 1: e000164. 10.1136/openhrt-2014-000164.
Coggon, D; Harris, EC; Poole, J; Palmer, KT. (2003). Extended follow-up of a cohort of British chemical workers exposed to formaldehyde. J Natl Cancer Inst 95: 1608–1615. 10.1093/jnci/djg046.14600093
Coggon, D; Ntani, G; Harris, EC; Palmer, KT. (2014). Upper Airway Cancer, Myeloid Leukemia, and Other Cancers in a Cohort of British Chemical Workers Exposed to Formaldehyde. Am J Epidemiol 179: 1301–1311. 10.1093/aje/kwu049.24714728
Cogliano, VJ; Baan, R; Straif, K; Grosse, Y; Lauby-Secretan, B; El Ghissassi, F; Bouvard, V; Benbrahim-Tallaa, L; Guha, N; Freeman, C; Galichet, L; Wild, CP. (2011). Preventable exposures associated with human cancers [Review]. J Natl Cancer Inst 103: 1827–1839. 10.1093/jnci/djr483.22158127
Cohen Hubal, EA; Schlosser, PM; Conolly, RB; Kimbell, JS. (1997). Comparison of inhaled formaldehyde dosimetry predictions with DNA-protein cross-link measurements in the rat nasal passages. Toxicol Appl Pharmacol 143: 47–55. 10.1006/taap.1996.8076.9073591
Cohn, L; Elias, JA; Chupp, GL. (2004). Asthma: mechanisms of disease persistence and progression [Review]. Annu Rev Immunol 22: 789–815. 10.1146/annurev.immunol.22.012703.104716.15032597
Collins, JJ; Acquavella, JF; Esmen, NA. (1997). An updated meta-analysis of formaldehyde exposure and upper respiratory tract cancers. J Occup Environ Med 39: 639–651. 10.1097/00043764-199707000-00009.9253725
Collins, JJ; Esmen, NA; Hall, TA. (2001). A review and meta-analysis of formaldehyde exposure and pancreatic cancer [Review]. Am J Ind Med 39: 336–345. 10.1002/1097-0274(200103)39:3<336::AID-AJIM1022>3.0.CO;2-K.11241567
Collins, JJ; Lineker, GA. (2004). A review and meta-analysis of formaldehyde exposure and leukemia [Review]. Regul Toxicol Pharmacol 40: 81–91. 10.1016/j.yrtph.2004.04.006.15450712
Comba, P; Barbieri, PG; Battista, G; Belli, S; Ponterio, F; Zanetti, D; Axelson, O. (1992a). Cancer of the nose and paranasal sinuses in the metal industry: a case-control study. Occup Environ Med 49: 193–196. 10.1136/oem.49.3.193.
Comba, P; Battista, G; Belli, S; Decapua, B; Merler, E; Orsi, D; Rodella, S; Vidigni, C; Axelson, O. (1992b). A case-control study of cancer of the nose and paranasal sinuses and occupational exposures. Am J Ind Med 22: 511–520. 10.1002/ajim.4700220406.1442786
Cometto-Muñiz, JE; Hernández, SM. (1990). Odorous and pungent attributes of mixed and unmixed odorants. Percept Psychophys 47: 391–399. 10.3758/bf03210879.2345692
Conolly, RB; Kimbell, JS; Janszen, D; Schlosser, PM; Kalisak, D; Preston, J; Miller, FJ. (2003). Biologically motivated computational modeling of formaldehyde carcinogenicity in the F344 rat. Toxicol Sci 75: 432–447. 10.1093/toxsci/kfg182.12857938
Conolly, RB; Kimbell, JS; Janszen, D; Schlosser, PM; Kalisak, D; Preston, J; Miller, FJ. (2004). Human respiratory tract cancer risks of inhaled formaldehyde: dose-response predictions derived from biologically-motivated computational modeling of a combined rodent and human dataset. Toxicol Sci 82: 279–296. 10.1093/toxsci/kfh223.15254341
Conolly, RB; Kimbell, JS; Janszen, DB; Miller, FJ. (2002). Dose response for formaldehyde-induced cytotoxicity in the human respiratory tract. Regul Toxicol Pharmacol 35: 32–43. 10.1006/rtph.2001.1515.11846634
Conolly, RB; Lilly, PD; Kimbell, JS. (2000). Simulation modelling of the tissue disposition of formaldehyde to predict nasal DNA-protein cross-links in Fischer 344 rats, rhesus monkeys, and humans. Environ Health Perspect 108: 919–924. 10.2307/3454325.
Coon, RA; Jones, RA; Jenkins, LJ, Jr; Siegel, J. (1970). Animal inhalation studies on ammonia, ethylene glycol, formaldehyde, dimethylamine, and ethanol. Toxicol Appl Pharmacol 16: 646–655. 10.1016/0041-008X(70)90069-4.4987187
Cooney, MA; Buck Louis, GM; Sundaram, R; Mcguiness, BM; Lynch, CD. (2009). Validity of self-reported time to pregnancy. Epidemiology 20: 56–59. 10.1097/EDE.0b013e31818ef47e.19057382
Corley, RA; Kabilan, S; Kuprat, AP; Carson, JP; Jacob, RE; Minard, KR; Teeguarden, JG; Timchalk, C; Pipavath, S; Glenny, R; Einstein, DR. (2015). Comparative risks of aldehyde constituents in cigarette smoke using transient computational fluid dynamics/physiologically based pharmacokinetic models of the rat and human respiratory tracts. Toxicol Sci 146: 65–88. 10.1093/toxsci/kfv071.25858911
Corthay, A. (2014). Does the immune system naturally protect against cancer? [Review]. 5: 197. 10.3389/fimmu.2014.00197.
Costa, S; Carvalho, S; Costa, C; Coelho, P; Silva, S; Santos, LS; Gaspar, JF; Porto, B; Laffon, B; Teixeira, JP. (2015). Increased levels of chromosomal aberrations and DNA damage in a group of workers exposed to formaldehyde. Mutagenesis 30: 463–473. 10.1093/mutage/gev002.25711496
Costa, S; Coelho, P; Costa, C; Silva, S; Mayan, O; Santos, LS; Gaspar, J; Teixeira, JP. (2008). Genotoxic damage in pathology anatomy laboratory workers exposed to formaldehyde. Toxicology 252: 40–48. 10.1016/j.tox.2008.07.056.18721846
Costa, S; Costa, C; Madureira, J; Valdiglesias, V; Teixeira-Gomes, A; Guedes de Pinho, P; Laffon, B; Teixeira, JP. (2019). Occupational exposure to formaldehyde and early biomarkers of cancer risk, immunotoxicity and susceptibility. Environ Res 179: 108740. 10.1016/j.envres.2019.108740.31563789
Costa, S; García-Lestón, J; Coelho, M; Coelho, P; Costa, C; Silva, S; Porto, B; Laffon, B; Teixeira, JP. (2013). Cytogenetic and immunological effects associated with occupational formaldehyde exposure. J Toxicol Environ Health A 76: 217–229. 10.1080/15287394.2013.757212.23514064
Coussens, LM; Werb, Z. (2002). Inflammation and cancer [Review]. Nature 420: 860–867. 10.1038/nature01322.12490959
Coussens, LM; Zitvogel, L; Palucka, AK. (2013a). Neutralizing tumor-promoting chronic inflammation: A magic bullet? [Review]. Science 339: 286–291. 10.1126/science.1232227.23329041
Coussens, LM; Zitvogel, L; Palucka, AK. (2013b). Neutralizing tumor-promoting chronic inflammation: A magic bullet? : Erratum [Erratum]. Science 339.
Cox, CP; Ruhl, DJ. (1966). Simplified computation of confidence intervals for relative potencies using Fieller’s theorem. J Pharm Sci 55: 368–371. 10.1002/jps.2600550403.5960286
Craig, EA; Schlesinger, MJ. (1985). The heat shock response. CRC Crit Rev Biochem 18: 239–280. 10.3109/10409238509085135.2412760
Crump, KS; Bussard, DA; Chen, C; Jinot, J; Subramaniam, R. (2014). The bottom-up approach does not necessarily bound low-dose risk [Letter]. Regul Toxicol Pharmacol 70: 735–736. 10.1016/j.yrtph.2014.10.008.25455229
Crump, KS; Chen, C; Chiu, WA; Louis, TA; Portier, CJ; Subramaniam, RP; White, PD. (2010). What role for biologically based dose-response models in estimating low-dose risk? [Review]. Environ Health Perspect 118: 585–588. 10.1289/ehp.0901249.20056564
Crump, KS; Chen, C; Fox, JF; Subramaniam, R; van Landingham, C. (2009). Reply to: Letter to the editor. Formaldehyde risk assessment [Letter]. Ann Occup Hyg 53: 181–189.19174485
Crump, KS; Chen, C; Fox, JF; Van Landingham, C; Sumbramaniam, R. (2008). Sensitivity analysis of biologically motivated model for formaldehyde-induced respiratory cancer in humans. Ann Occup Hyg 52: 481–495. 10.1093/annhyg/men038.18628253
Crump, KS; Subramaniam, RP; Van Landingham, CB. (2005). A numerical solution to the nonhomogeneous two-stage MVK model of cancer. Risk Anal 25: 921–926. 10.1111/j.1539-6924.2005.00651.x.16268939
Curado, MP; Shin, HR; Storm, H; Ferlay, J; Heanue, M; Boyle, P. (2007). Cancer incidence in five continents, Vol. IX [IARC Monograph]. In Cancer Incidence in Five Continents Vol IX. (IARC Scientific Publication No. 160). Lyon, France: International Agency for Research on Cancer (IARC).
D’Errico, A; Pasian, S; Baratti, A; Zanelli, R; Alfonzo, S; Gilardi, L; Beatrice, F; Bena, A; Costa, G. (2009). A case-control study on occupational risk factors for sino-nasal cancer. Occup Environ Med 66: 448–455. 10.1136/oem.2008.041277.19153109
Dalbey, WE. (1982). Formaldehyde and tumors in hamster respiratory tract. Toxicology 24: 9–14. 10.1016/0300-483X(82)90058-0.7135407
Dally, KA; Hanrahan, LP; Woodbury, MA; Kanarek, MS. (1981). Formaldehyde exposure in nonoccupational environments. Arch Environ Occup Health 36: 277–284. 10.1080/00039896.1981.10667638.
Dannemiller, KC; Murphy, JS; Dixon, SL; Pennell, KG; Suuberg, EM; Jacobs, DE; Sandel, M. (2013). Formaldehyde concentrations in household air of asthma patients determined using colorimetric detector tubes. Indoor Air 23: 285–294. 10.1111/ina.12024.23278296
Day, JH; Lees, RE; Clark, RH; Pattee, PL. (1984). Respiratory response to formaldehyde and off-gas of urea formaldehyde foam insulation. Can Med Assoc J 131: 1061–1065.6388780
de Graaf, B; Clore, A; Mccullough, AK. (2009). Cellular pathways for DNA repair and damage tolerance of formaldehyde-induced DNA-protein crosslinks. DNA Repair 8: 1207–1214. 10.1016/j.dnarep.2009.06.007.19625222
de Kruijf, EJ; Alkemade, GM; van Os, R; Fibbe, WE; van Pel, M. (2014). Peripheral blood hematopoietic stem and progenitor cell frequency is unchanged in patients with alpha-1-antitrypsin deficiency. Int J Hematol 99: 714–720. 10.1007/s12185-014-1581-3.24752699
Dean, JH; Lauer, LD; House, RV; Murray, MJ; Stillman, WS; Irons, RD; Steinhagen, WH; Phelps, MC; Adams, DO. (1984). Studies of immune fuction and host resistance in B6C3F1 mice exposed to formaldehyde. Toxicol Appl Pharmacol 72: 519–529. 10.1016/0041-008X(84)90129-7.6424265
Dell, L; Teta, MJ. (1995). Mortality among workers at a plastics manufacturing and research and development facility: 1946-1988. Am J Ind Med 28: 373–384. 10.1002/ajim.4700280307.7485191
Deltour, L; Foglio, MH; Duester, G. (1999). Metabolic deficiencies in alcohol dehydrogenase Adh1, Adh3, and Adh4 null mutant mice. Overlapping roles of Adh1 and Adh4 in ethanol clearance and metabolism of retinol to retinoic acid. J Biol Chem 274: 16796–16801. 10.1074/jbc.274.24.16796.10358022
DeMarini, DM; Shelton, ML; Kohan, MJ; Hudgens, EE; Kleindienst, TE; Ball, LM; Walsh, D; de Boer, JG; Lewis-Bevan, L; Rabinowitz, J. R.; Claxton, LD; Lewtas, J. (2000). Mutagenicity in lung of Big Blue(R) mice and induction of tandem-base substitutions in Salmonella by the air pollutant peroxyacetyl nitrate (PAN): Predicted formation of intrastrand cross-links. Mutat Res Fundam Mol Mech Mutagen 457: 41–55. 10.1016/S0027-5107(00)00121-4.
DHGC (DuPont Haskell Global Centers). (2010). [Two Acute/ Subacute Inhalation toxicity studies].
Dingler, FA; Wang, M; Mu, A; Millington, CL; Oberbeck, N; Watcham, S; Pontel, LB; Kamimae-Lanning, AN; Langevin, F; Nadler, C; Cordell, RL; Monks, PS; Yu, R; Wilson, NK; Hira, A; Yoshida, K; Mori, M; Okamoto, Y; Okuno, Y; Muramatsu, H; Shiraishi, Y; Kobayashi, M; Moriguchi, T; Osumi, T; Kato, M; Miyano, S; Ito, E; Kojima, S; Yabe, H; Yabe, M; Matsuo, K; Ogawa, S; Göttgens, B; Hodskinson, MRG; Takata, M; Patel, KJ. (2020). Two aldehyde clearance systems are essential to prevent lethal formaldehyde accumulation in mice and humans. Mol Cell 80: 996–1012.e1019. 10.1016/j.molcel.2020.10.012.33147438
Dinsdale, D; Riley, RA; Verschoyle, RD. (1993). Pulmonary cytochrome P450 in rats exposed to formaldehyde vapor. Environ Res 62: 19–27. 10.1006/enrs.1993.1085.8100769
Dix, DJ. (1997). Hsp 70 expression and function during gametogenesis. Cell Stress Chaperones 2: 73. 10.1379/1466-1268(1997)002<0073:heafdg>2.3.co;2.9250397
Dix, DJ; Allen, JW; Collins, BW; Poorman-Allen, P; Mori, C; Blizard, DR; Brown, PR; Goulding, EH; Strong, BD; Eddy, EM. (1997). HSP70-2 is required for desynapsis of synaptonemal complexes during meiotic prophase in juvenile and adult mouse spermatocytes. Development 124: 4595–4603.9409676
Doi, S; Suzuki, S; Morishita, M; Yamada, M; Kanda, Y; Torii, S; Sakamoto, T. (2003). The prevalence of IgE sensitization to formaldehyde in asthmatic children. Allergy 58: 668–671. 10.1034/j.1398-9995.2003.00044.x.12823129
Dotterud, LK; Kvammen, B; Lund, E; Falk, ES. (1995). An evaluation of atopic diseases in relation to immediate skin test reactions among schoolchildren in the Sor-Varanger community. J Eur Acad Dermatol Venereol 5: 240–249. 10.1111/j.1468-3083.1995.tb00112.x.
Douglas, SD; Lai, JP; Tuluc, F; Schwartz, L; Kilpatrick, LE. (2008). Neurokinin-1 receptor expression and function in human macrophages and brain: perspective on the role in HIV neuropathogenesis. Ann N Y Acad Sci 1144: 90–96. 10.1196/annals.1418.007.19076368
Duong, A; Steinmaus, C; Mchale, CM; Vaughan, CP; Zhang, L. (2011). Reproductive and developmental toxicity of formaldehyde: a systematic review [Review]. Mutat Res 728: 118–138. 10.1016/j.mrrev.2011.07.003.21787879
Dutta, R; Dubal, PM; Svider, PF; Liu, JK; Baredes, S; Eloy, JA. (2015). Sinonasal malignancies: A population-based analysis of site-specific incidence and survival. Laryngoscope 125: 2491–2497. 10.1002/lary.25465.26228792
Dykewicz, MS; Patterson, R; Cugell, DW; Harris, KE; Wu, AF. (1991). Serum IgE and IgG to formaldehyde-human serum albumin: Lack of relation to gaseous formaldehyde exposure and symptoms. J Allergy Clin Immunol 87: 48–57. 10.1016/0091-6749(91)90212-7.1991923
Dzirasa, K; Ribeiro, S; Costa, R; Santos, LM; Lin, SC; Grosmark, A; Sotnikova, TD; Gainetdinov, RR; Caron, MG; Nicolelis, MA. (2006). Dopaminergic control of sleep-wake states. J Neurosci 26: 10577–10589. 10.1523/JNEUROSCI.1767-06.2006.17035544
Eastmond, DA. (1997). Chemical and Radiation Leukemogenesis in Humans and Rodents and the Value of Rodent Models for Assessing Risks of Lymphohematopoietic Cancers. (NTIS/02999382). Eastmond, DA.
Eastmond, DA; Keshava, N; Sonawane, B. (2014). Lymphohematopoietic cancers induced by chemicals and other agents and their implications for risk evaluation: An overview [Review]. Mutat Res Rev Mutat Res 761: 40–64. 10.1016/j.mrrev.2014.04.001.24731989
ECHA (European Chemicals Agency). (2012). Committee for risk assessment. RAC. Opinion proposing harmonized classification and labeling at EU level of formaldehyde. (CLH-O-0000003155-80-01/F). Helsinki, Finland. https://echa.europa.eu/documents/10162/b8dfa022-9544-72e8-dcaa-7491dff3c0d5.
Edling, C; Hellquist, H; Odkvist, L. (1987a). Occupational formaldehyde exposure and the nasal mucosa. Rhinology 25: 181–187.3672002
Edling, C; Hellquist, H; Odkvist, L. (1988). Occupational exposure to formaldehyde and histopathological changes in the nasal mucosa. Br J Ind Med 45: 761–765. 10.1136/oem.45.11.761.3203081
Edling, C; Järvholm, B; Andersson, L; Axelson, O. (1987b). Mortality and cancer incidence among workers in an abrasive manufacturing industry. Br J Ind Med 44: 57–59. 10.1136/oem.44.1.57.3814536
Edrissi, B; Taghizadeh, K; Dedon, PC. (2013a). Quantitative analysis of histone modifications: formaldehyde is a source of pathological n(6)-formyllysine that is refractory to histone deacetylases. PLoS Genet 9: e1003328. 10.1371/journal.pgen.1003328.23468656
Edrissi, B; Taghizadeh, K; Moeller, BC; Kracko, D; Doyle-Eisele, M; Swenberg, JA; Dedon, PC. (2013b). Dosimetry of N^6^-formyllysine adducts following [^13^C^2^H_2_]-formaldehyde exposures in rats. Chem Res Toxicol 26: 1421–1423. 10.1021/tx400320u.24087891
Egle, JL, Jr. (1972). Retention of inhaled formaldehyde, propionaldehyde, and acrolein in the dog. Arch Environ Health 25: 119–124. 10.1080/00039896.1972.10666147.5045063
EHS Consultants Ltd. (EHS Consultants Limited). (1999). Consultancy study for indoor air pollution in offices and public places in Hong Kong (Agreement no. CE 14/95). Hong Kong: Environmental Protection Department.
El-Zein, RA; Schabath, MB; Etzel, CJ; Lopez, MS; Franklin, JD; Spitz, MR. (2006). Cytokinesis-blocked micronucleus assay as a novel biomarker for lung cancer risk. Cancer Res 66: 6449–6456. 10.1158/0008-5472.CAN-06-0326.16778224
Elenkov, IJ; Wilder, RL; Chrousos, GP; Vizi, ES. (2000). The sympathetic nerve--an integrative interface between two supersystems: the brain and the immune system [Review]. Pharmacol Rev 52: 595–638.11121511
Erb, KJ; Le Gros, G. (1996). The role of Th2 type CD4+ T cells and Th2 type CD8+ T cells in asthma [Review]. Immunol Cell Biol 74: 206–208. 10.1038/icb.1996.29.8724011
Erdei, E; Bobvos, J; Brózik, M; Páldy, A; Farkas, I; Vaskövi, E; Rudnai, P. (2003). Indoor air pollutants and immune biomarkers among Hungarian asthmatic children. Arch Environ Occup Health 58: 337–347.
Ericson, A; Eriksson, M; Källén, B; Westerholm, P; Zetterström, R. (1984). Delivery outcome of women working in laboratories during pregnancy. Arch Environ Health 39: 5–10.6712285
Escanilla, O; Yuhas, C; Marzan, D; Linster, C. (2009). Dopaminergic modulation of olfactory bulb processing affects odor discrimination learning in rats. Behav Neurosci 123: 828–833. 10.1037/a0015855.19634942
Ezratty, V; Bonay, M; Neukirch, C; Orset-Guillossou, G; Dehoux, M; Koscienlny, S; Cabanes, PA; Lambrozo, J; Aubier, M. (2007). Effect of formaldehyde on asthmatic response to inhaled allergen challenge. Environ Health Perspect 115: 210–214. 10.1289/ehp.9414.17384766
Fabbri, M; Garzon, R; Cimmino, A; Liu, Z; Zanesi, N; Callegari, E; Liu, S; Alder, H; Costinean, S; Fernandez-Cymering, C; Volinia, S; Guler, G; Morrison, CD; Chan, KK; Marcucci, G; Calin, GA; Huebner, K; Croce, CM. (2007). MicroRNA-29 family reverts aberrant methylation in lung cancer by targeting DNA methyltransferases 3A and 3B. Proc Natl Acad Sci USA 104: 15805–15810. 10.1073/pnas.0707628104.17890317
Falk, JE; Juto, JE; Stridh, G; Bylin, G. (1994). Dose-response study of formaldehyde on nasal mucosa swelling. A study on residents with nasal distress at home. Am J Rhinol Allergy 8: 143–146. 10.2500/105065894781874412.
Fang, F; Quinlan, P; Ye, W; Barber, MK; Umbach, DM; Sandler, DP; Kamel, F. (2009). Workplace exposures and the risk of amyotrophic lateral sclerosis. Environ Health Perspect 117: 1387–1392. 10.1289/ehp.0900580.19750102
Fantel, AG; Macphail, BJ. (1982). THE TERATOGENICITY OF COCAINE. Teratology 26: 17–19. 10.1002/tera.1420260104.7135254
Farrand, KF; Fridman, M; Stillman, IÖ; Schaumberg, DA. (2017). Prevalence of diagnosed dry eye disease in the United States among adults aged 18 years and older. Am J Ophthalmol 182: 90–98. 10.1016/j.ajo.2017.06.033.28705660
Fenech, M. (2020). Cytokinesis-Block Micronucleus Cytome Assay Evolution into a More Comprehensive Method to Measure Chromosomal Instability [Review]. Genes 11. 10.3390/genes11101203.
Fenech, M; Holland, N; Zeiger, E; Chang, WP; Burgaz, S; Thomas, P; Bolognesi, C; Knasmueller, S; Kirsch-Volders, M; Bonassi, S. (2011). The HUMN and HUMNxL international collaboration projects on human micronucleus assays in lymphocytes and buccal cells--past, present and future [Review]. Mutagenesis 26: 239–245. 10.1093/mutage/geq051.21164208
Feron, VJ; Bruyntjes, JP; Woutersen, RA; Immel, HR; Appelman, LM. (1988). Nasal tumours in rats after short-term exposure to a cytotoxic concentration of formaldehyde. Cancer Lett 39: 101–111. 10.1016/0304-3835(88)90045-6.3345504
Ferris, BG. (1978). Epidemiology standardization project (American Thoracic Society). Am Rev Respir Dis 118: 1–120.
Fishbein, L. (1992). Exposure from occupational versus other sources [Review]. Scand J Work Environ Health 18: 5–16.
Flamant-Hulin, M; Caillaud, D; Sacco, P; Pénard-Morand, C; Annesi-Maesano, I. (2010). Air pollution and increased levels of fractional exhaled nitric oxide in children with no history of airway damage. J Toxicol Environ Health A 73: 272–283. 10.1080/15287390903249206.20077297
Fox, EM. (1985). Urea formaldehyde foam insulation: defusing a timebomb. Am J Law Med 11: 81–104.3832945
Franklin, P; Dingle, P; Stick, S. (2000). Raised exhaled nitric oxide in healthy children is associated with domestic formaldehyde levels. Am J Respir Crit Care Med 161: 1575–1759. 10.1164/ajrccm.161.5.9905061.
Franklin, P; Tan, M; Hemy, N; Hall, GL. (2019). Maternal Exposure to Indoor Air Pollution and Birth Outcomes. Int J Environ Res Public Health 16. 10.3390/ijerph16081364.
Fransman, W; Mclean, D; Douwes, J; Demers, PA; Leung, V; Pearce, N. (2003). Respiratory symptoms and occupational exposures in New Zealand plywood mill workers. Ann Occup Hyg 47: 287–295. 10.1093/annhyg/meg046.12765869
French, JE; Gatti, DM; Morgan, DL; Kissling, GE; Shockley, KR; Knudsen, GA; Shepard, KG; Price, HC; King, D; Witt, KL; Pedersen, LC; Munger, SC; Svenson, KL; Churchill, GA. (2015). Diversity outbred mice identify population-based exposure thresholds and genetic factors that influence benzene-induced genotoxicity. Environ Health Perspect 123: 237–245. 10.1289/ehp.1408202.25376053
Fryzek, JP; Chadda, BK; Cohen, SS; Marano, D; White, K; Steinwandel, M; Mclaughlin, JK. (2005). Retrospective cohort mortality study of workers engaged in motion picture film processing. J Occup Environ Med 47: 278–286. 10.1097/01.jom.0000155712.22617.42.15761324
Fujimaki, H; Kurokawa, Y; Kakeyama, M; Kunugita, N; Fueta, Y; Fukuda, T; Hori, H; Arashidani, K. (2004a). Inhalation of low-level formaldehyde enhances nerve growth factor production in the hippocampus of mice. Neuroimmunomodulation 11: 373–375. 10.1159/000080147.15467352
Fujimaki, H; Kurokawa, Y; Kunugita, N; Kikuchi, M; Sato, F; Arashidani, K. (2004b). Differential immunogenic and neurogenic inflammatory responses in an allergic mouse model exposed to low levels of formaldehyde. Toxicology 197: 1–13. 10.1016/j.tox.2003.11.015.15003329
Gamble, JF; Mcmichael, AJ; Williams, T; Battigelli, M. (1976). Respiratory function and symptoms: an environmental-epidemiological study of rubber workers exposed to a phenolformaldehyde type resin. Am Ind Hyg Assoc J 37: 499–513. 10.1080/0002889768507508.1008033
Gandhi, M; Aweeka, F; Greenblatt, RM; Blaschke, TF. (2004). Sex differences in pharmacokinetics and pharmacodynamics [Review]. Annu Rev Pharmacol Toxicol 44: 499–523. 10.1146/annurev.pharmtox.44.101802.121453.14744256
Garaycoechea, JI; Crossan, GP; Langevin, F; Daly, M; Arends, MJ; Patel, KJ. (2012). Genotoxic consequences of endogenous aldehydes on mouse haematopoietic stem cell function. Nature 489: 571–575. 10.1038/nature11368.22922648
García-Calderón, CB; Bejarano-García, JA; Tinoco-Gago, I; Castro, MJ; Moreno-Gordillo, P; Piruat, JI; Caballero-Velázquez, T; Pérez-Simón, JA; Rosado, IV. (2018). Genotoxicity of tetrahydrofolic acid to hematopoietic stem and progenitor cells. Cell Death Differ 25: 1967–1979. 10.1038/s41418-018-0089-4.29511342
Garcia, GJM; Schroeter, JD; Segal, RA; Stanek, J; Foureman, GL; Kimbell, JS. (2009). Dosimetry of nasal uptake of water-soluble and reactive gases: A first study of interhuman variability. Inhal Toxicol 21: 607–618. 10.1080/08958370802320186.19459775
Gardner, MJ; Pannett, B; Winter, PD; Cruddas, AM. (1993). A cohort study of workers exposed to formaldehyde in the British chemical industry: An update. Br J Ind Med 50: 827–834. 10.1136/oem.50.9.827.8398877
Garrett, MH; Hooper, MA; Hooper, BM; Rayment, PR; Abramson, MJ. (1999). Increased risk of allergy in children due to formaldehyde exposure in homes. Allergy 54: 330–337. 10.1034/j.1398-9995.1999.00763.x.10371091
Garzon, R; Heaphy, CEA; Havelange, V; Fabbri, M; Violinia, S; Tsao, T; Zanesi, H; Kornblau, SM; Marcucci, G; Calin, GA; Andreeff, M; Croce, CM. (2009). MicroRNA 29b functions in acute myeloid leukemia. Blood 114: 5331–5341. 10.1182/blood-2009-03-211938.19850741
Gee, IL; Watson, AFR; Tavernier, G; Stewart, LJ; Fletcher, G; Niven, RM. (2005). Indoor air quality, environmental tobacco smoke and asthma: A case control study of asthma in a community population. Indoor Built Environ 14: 215–219. 10.1177/1420326X05054288.
Gentry, PR; Rodricks, JV; Turnbull, D; Bachand, A; Van Landingham, C; Shipp, AM; Albertini, RJ; Irons, R. (2013). Formaldehyde exposure and leukemia: Critical review and reevaluation of the results from a study that is the focus for evidence of biological plausibility [Review]. Crit Rev Toxicol 43: 661–670. 10.3109/10408444.2013.818618.23902349
George, L; Brightling, CE. (2016). Eosinophilic airway inflammation: role in asthma and chronic obstructive pulmonary disease [Review]. 7: 34–51. 10.1177/2040622315609251.
Gerard, C. (2005). Biomedicine. Asthmatics breathe easier when it’s SNO-ing [Comment]. Science 308: 1560–1561. 10.1126/science.1114163.15947161
Gérin, M; Siemiatycki, J; Nadon, L; Dewar, R; Krewski, D. (1989). Cancer risks due to occupational exposure to formaldehyde: Results of a multi-site case-control study in Montreal. Int J Cancer 44: 53–58. 10.1002/ijc.2910440110.2744897
Giavina-Bianchi, P; Aun, MV; Takejima, P; Kalil, J; Agondi, RC. (2016). United airway disease: current perspectives [Review]. Journal of Asthma and Allergy 9: 93–100. 10.2147/JAA.S81541.27257389
Gieroba, ZJ; Yu, YH; Blessing, WW. (1994). Vasoconstriction induced by inhalation of irritant vapour is associated with appearance of Fos protein in C1 catecholamine neurons in rabbit medulla oblongata. Brain Res 636: 157–161. 10.1016/0006-8993(94)90192-9.7908852
Ginsberg, G; Guyton, K; Johns, D; Schimek, J; Angle, K; Sonawane, B. (2010). Genetic polymorphism in metabolism and host defense enzymes: Implications for human health risk assessment [Review]. Crit Rev Toxicol 40: 575–619. 10.3109/10408441003742895.20662711
Ginsberg, GL; Asgharian, B; Kimbell, JS; Ultman, JS; Jarabek, AM. (2008). Modeling approaches for estimating the dosimetry of inhaled toxicants in children [Review]. J Toxicol Environ Health A 71: 166–195. 10.1080/15287390701597889.18097944
Ginsberg, GL; Foos, BP; Firestone, MP. (2005). Review and analysis of inhalation dosimetry methods for application to children’s risk assessment [Review]. J Toxicol Environ Health A 68: 573–615. 10.1080/15287390590921793.15901090
Gochfeld, M. (2007). Framework for gender differences in human and animal toxicology [Review]. Environ Res 104: 4–21. 10.1016/j.envres.2005.12.005.16616135
Gofmekler, VA; Pushkina, NN; Klevtsova, GN. (1968). [Various biochemical shifts during a study of the embryotropic effect of benzene and formaldehyde]. Gig Sanit 33: 96–98.
Golalipour, MJ; Azarhoush, R; Ghafari, S; Gharravi, AM; Fazeli, SA; Davarian, A. (2007). Formaldehyde exposure induces histopathological and morphometric changes in the rat testis. Folia Morphol (Warsz) 66: 167–171.17985313
Goldstein, BD. (2011). Hematological and toxicological evaluation of formaldehyde as a potential cause of human leukemia [Review]. Hum Exp Toxicol 30: 725–735. 10.1177/0960327110381682.20729258
Goodson, WH; Lowe, L; Carpenter, DO; Gilbertson, M; Manaf Ali, A; Lopez de Cerain Salsamendi, A; Lasfar, A; Carnero, A; Azqueta, A; Amedei, A; Charles, AK; Collins, AR; Ward, A; Salzberg, AC; Colacci, A; Olsen, AK; Berg, A; Barclay, BJ; Zhou, BP; Blanco-Aparicio, C; Baglole, CJ; Dong, C; Mondello, C; Hsu, CW; Naus, CC; Yedjou, C; Curran, CS; Laird, DW; Koch, DC; Carlin, DJ; Felsher, DW; Roy, D; Brown, DG; Ratovitski, E; Ryan, EP; Corsini, E; Rojas, E; Moon, EY; Laconi, E; Marongiu, F; Al-Mulla, F; Chiaradonna, F; Darroudi, F; Martin, FL; Van Schooten, FJ; Goldberg, GS; Wagemaker, G; Nangami, GN; Calaf, GM; Williams, G; Wolf, GT; Koppen, G; Brunborg, G; Lyerly, HK; Krishnan, H; Ab Hamid, H; Yasaei, H; Sone, H; Kondoh, H; Salem, HK; Hsu, HY; Park, HH; Koturbash, I; Miousse, IR; Scovassi, AI; Klaunig, JE; Vondráček, J; Raju, J; Roman, J; Wise, JP; Whitfield, J. R.; Woodrick, J; Christopher, JA; Ochieng, J; Martinez-Leal, JF; Weisz, J; Kravchenko, J; Sun, J; Prudhomme, KR; Narayanan, KB; Cohen-Solal, KA; Moorwood, K; Gonzalez, L; Soucek, L; Jian, L; D’Abronzo, LS; Lin, LT; Li, L; Gulliver, L; Mccawley, LJ; Memeo, L; Vermeulen, L; Leyns, L; Zhang, L; Valverde, M; Khatami, M; Romano, MF; Chapellier, M; Williams, MA; Wade, M; Manjili, MH; Lleonart, ME; Xia, M; Gonzalez, MJ; Karamouzis, MV; Kirsch-Volders, M; Vaccari, M; Kuemmerle, NB; Singh, N; Cruickshanks, N; Kleinstreuer, N; van Larebeke, N; Ahmed, N; Ogunkua, O; Krishnakumar, PK; Vadgama, P; Marignani, PA; Ghosh, PM; Ostrosky-Wegman, P; Thompson, PA; Dent, P; Heneberg, P; Darbre, P; Sing Leung, P; Nangia-Makker, P; Cheng, QS; Robey, RB; Al-Temaimi, R; Roy, R; Andrade-Vieira, R; Sinha, RK; Mehta, R; Vento, R; Di Fiore, R; Ponce-Cusi, R; Dornetshuber-Fleiss, R; Nahta, R; Castellino, RC; Palorini, R; Abd Hamid, R; Langie, SA; Eltom, SE; Brooks, SA; Ryeom, S; Wise, SS; Bay, SN; Harris, SA; Papagerakis, S; Romano, S; Pavanello, S; Eriksson, S; Forte, S; Casey, SC; Luanpitpong, S; Lee, TJ; Otsuki, T; Chen, T; Massfelder, T; Sanderson, T; Guarnieri, T; Hultman, T; Dormoy, V; Odero-Marah, V; Sabbisetti, V; Maguer-Satta, V; Rathmell, WK; Engström, W; Decker, WK; Bisson, WH; Rojanasakul, Y; Luqmani, Y; Chen, Z; Hu, Z. (2015). Assessing the carcinogenic potential of low-dose exposures to chemical mixtures in the environment: the challenge ahead [Review]. Carcinogenesis 36 Suppl 1: S254–S296. 10.1093/carcin/bgv039.26106142
Górski, P; Krakowiak, A. (1991). Formaldehyde--induced bronchial asthma--does it really exist? Pol J Occup Med Environ Health 4: 317–320.1817680
Grammer, LC; Harris, KE; Shaughnessy, MA; Sparks, P; Ayars, GH; Altman, LC; Patterson, R. (1990). Clinical and immunologic evaluation of 37 workers exposed to gaseous formaldehyde. J Allergy Clin Immunol 86: 177–181. 10.1016/S0091-6749(05)80063-6.2384647
Granick, JL; Simon, SI; Borjesson, DL. (2012). Hematopoietic stem and progenitor cells as effectors in innate immunity. 2012: 165107. 10.1155/2012/165107.
Greaves, M. (1999). Molecular genetics, natural history and the demise of childhood leukaemia. Eur J Cancer 35: 173–185. 10.1016/S0959-8049(98)00433-X.10448256
Greaves, MF. (2004). Biological models for leukemia and lymphoma. In P Buffler; JM Rice; R Baan; M Bird; P Boffetta (Eds.), Mechanisms of carcinogenesis: Contributions of molecular epidemiology (pp. 351–372). Lyon, France: International Agency for Research on Cancer.
Green, DJ; Bascom, R; Healey, EM; Hebel, JR; Sauder, LR; Kulle, TJ. (1989). Acute pulmonary response in healthy, nonsmoking adults to inhalation of formaldehyde and carbon. J Toxicol Environ Health 28: 261–275. 10.1080/15287398909531347.2585534
Green, DJ; Sauder, LR; Kulle, TJ; Bascom, R. (1987). Acute response to 3.0 ppm formaldehyde in exercising healthy nonsmokers and asthmatics. Am Rev Respir Dis 135: 1261–1266. 10.1164/arrd.1987.135.6.1261.3592401
Gu, Y; Fujimiya, Y; Kunugita, N. (2008). Long-term exposure to gaseous formaldehyde promotes allergen-specific IgE-mediated immune responses in a murine model. Hum Exp Toxicol 27: 37–43. 10.1177/0960327108088973.18480147
Gustafson, P; Barregård, L; Lindahl, R; Sällsten, G. (2005). Formaldehyde levels in Sweden: Personal exposure, indoor, and outdoor concentrations. J Expo Anal Environ Epidemiol 15: 252–260. 10.1038/sj.jea.7500399.15305169
Gustavsson, P; Jakobsson, R; Johansson, H; Lewin, F; Norell, S; Rutkvist, LE. (1998). Occupational exposures and squamous cell carcinoma of the oral cavity, pharynx, larynx, and oesophagus: A case-control study in Sweden. Occup Environ Med 55: 393–400.9764099
Hall, A; Harrington, JM; Aw, TC. (1991). Mortality study of British pathologists. Am J Ind Med 20: 83–89. 10.1002/ajim.4700200108.1867220
Hamelmann, E; Vella, AT; Oshiba, A; Kappler, JW; Marrack, P; Gelfand, EW. (1997). Allergic airway sensitization induces T cell activation but not airway hyperresponsiveness in B cell-deficient mice. Proc Natl Acad Sci USA 94: 1350–1355.9037056
Han, P; Zhao, J; Liu, SB; Yang, CJ; Wang, YQ; Wu, GC; Xu, DM; Mi, WL. (2013). Interleukin-33 mediates formalin-induced inflammatory pain in mice. Neuroscience 241: 59–66. 10.1016/j.neuroscience.2013.03.019.23523996
Han, SP; Zhou, DX; Lin, P; Qin, Z; An, L; Zheng, LR; Lei, L. (2015). Formaldehyde exposure induces autophagy in testicular tissues of adult male rats. Environ Toxicol 30: 323–331. 10.1002/tox.21910.24142868
Hanahan, D; Weinberg, RA. (2000). The hallmarks of cancer [Review]. Cell 100: 57–70. 10.1016/S0092-8674(00)81683-9.10647931
Hanahan, D; Weinberg, RA. (2011). Hallmarks of cancer: The next generation [Review]. Cell 144: 646–674. 10.1016/j.cell.2011.02.013.21376230
Hankinson, JL; Odencrantz, JR; Fedan, KB. (1999). Spirometric reference values from a sample of the general US population. Am J Respir Crit Care Med 159: 179–187. 10.1164/ajrccm.159.1.9712108.9872837
Hanrahan, LP; Dally, KA; Anderson, HA; Kanarek, MS; Rankin, J. (1984). Formaldehyde vapor in mobile homes: A cross sectional survey of concentrations and irritant effects. Am J Public Health 74: 1026–1027. 10.2105/ajph.74.9.1026.6331773
Hansen, J; Olsen, JH. (1995). Formaldehyde and cancer morbidity among male employees in Denmark. Cancer Causes Control 6: 354–360. 10.1007/BF00051411.7548723
Hansen, J; Olsen, JH; Larsen, AI. (1994). Cancer morbidity among employees in a Danish pharmaceutical plant. Int J Epidemiol 23: 891–898. 10.1093/ije/23.5.891.7860168
Hardell, L; Johansson, B; Axelson, O. (1982). Epidemiological study of nasal and nasopharyngeal cancer and their relation to phenoxy acid or chlorophenol exposure. Am J Ind Med 3: 247–257. 10.1002/ajim.4700030304.6303119
Harkema, JR; Carey, SA; Wagner, JG. (2006). The nose revisited: A brief overview of the comparative structure, function, and toxicologic pathology of the nasal epithelium [Review]. Toxicol Pathol 34: 252–269. 10.1080/01926230600713475.16698724
Harkema, JR; Nikula, KJ; Haschek, WM. (2013). Respiratory system. In W Haschek; C Rousseaux; M Wallig (Eds.), Haschek and Rousseaux’s handbook of toxicologic pathology (3rd ed., pp. 1935–2003). Waltham, MA: Academic Press. 10.1016/B978-0-12-415759-0.00051-0.
Harrington, JM; Oakes, D. (1984). Mortality study of British pathologists 1974-80. Occup Environ Med 41: 188–191. 10.1136/oem.41.2.188.
Harris, NL; Stein, H; Coupland, SE; Hummel, M; Favera, RD; Pasqualucci, L; Chan, WC. (2001). New approaches to lymphoma diagnosis [Review]. Hematology Am Soc Hematol Educ Program 194–220.11722985
Harving, H; Korsgaard, J; Dahl, R; Pedersen, OF; Molhave, L. (1986). Low concentrations of formaldehyde in bronchial asthma: a study of exposure under controlled conditions. Br Med J 293: 310.3089500
Harving, H; Korsgaard, J; Pedersen, OF; Mølhave, L; Dahl, R. (1990). Pulmonary function and bronchial reactivity in asthmatics during low-level formaldehyde exposure. Lung 168: 15–21. 10.1007/BF02719669.2105409
Haseman, JK; Hailey, JR. (1997). An update of the National Toxicology Program database on nasal carcinogens. Mutat Res 380: 3–11. 10.1016/S0027-5107(97)00121-8.9385384
Hauptmann, M; Lubin Jay, H; Stewart, PA; Hayes, RB; Blair, A. (2003). Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries. J Natl Cancer Inst 95: 1615–1623. 10.1093/jnci/djg083.14600094
Hauptmann, M; Lubin, JH; Stewart, PA; Hayes, RB; Blair, A. (2004). Mortality from solid cancers among workers in formaldehyde industries. Am J Epidemiol 159: 1117–1130. 10.1093/aje/kwh174.15191929
Hauptmann, M; Stewart, PA; Lubin, JH; Beane Freeman, LE; Hornung, RW; Herrick, RF; Hoover, RN; Fraumeni, JF, Jr; Blair, A; Hayes, RB. (2009). Mortality from lymphohematopoietic malignancies and brain cancer among embalmers exposed to formaldehyde. J Natl Cancer Inst 101: 1696–1708. 10.1093/jnci/djp416.19933446
Hayashi, H; Kunugita, N; Arashidani, K; Fujimaki, H; Ichikawa, M. (2004). Long-term exposure to low levels of formaldehyde increases the number of tyrosine hydroxylase-immunopositive periglomerular cells in mouse main olfactory bulb. Brain Res 1007: 192–197. 10.1016/j.brainres.2003.12.052.15064152
Hayes, RB; Blair, A; Stewart, PA; Herrick, RF; Mahar, H. (1990). Mortality of U.S. embalmers and funeral directors. Am J Ind Med 18: 641–652. 10.1002/ajim.4700180603.2264563
Hayes, RB; Gerin, M; Raatgever, JW; de Bruyn, A. (1986a). Wood-related occupations, wood dust exposure, and sinonasal cancer. Am J Epidemiol 124: 569–577. 10.1093/oxfordjournals.aje.a114429.3752051
Hayes, RB; Raatgever, JW; de Bruyn, A; Gerin, M. (1986b). Cancer of the nasal cavity and paranasal sinuses, and formaldehyde exposure. Int J Cancer 37: 487–492. 10.1002/ijc.2910370403.3957459
He, HJ; Liu, HL; Wu, J; Lu, ZS; Yan, Y; Yang, X; Li, CM. (2005). A study on the acute irritation responses and molecular mechanism of gaseous formaldehyde. In X Yang; B Zhao; R Zhao (Eds.), Indoor Air 2005: Proceedings of the 10th International Conference on Indoor Air Quality and Climate, vol 5 (pp. 3691–3695). Beijing, China: Tsinghua University Press. https://www.isiaq.org/docs/PDFs/3691.pdf.
Health Canada. (2001). Priority substances list assessment report Formaldehyde. Hull, Quebec, Canada: Environment Canada and Health Canada.
Health Canada. (2006). Residential indoor air quality guideline. Formaldehyde. http://healthycanadians.gc.ca/publications/healthy-living-vie-saine/formaldehyde/alt/formaldehyde-eng.pdf.
Heck, H; Casanova-Schmitz, M; Dodd, PB; Schachter, EN; Witek, TJ; Tosun, T. (1985). Formaldehyde (CH2O) concentrations in the blood of humans and Fischer-344 rats exposed to CH2O under controlled conditions. AIHA J 46: 1–3. 10.1080/15298668591394275.
Heck, H; Casanova, M. (1999). Pharmacodynamics of formaldehyde: Applications of a model for the arrest of DNA replication by DNA-protein cross-links. Toxicol Appl Pharmacol 160: 86–100. 10.1006/taap.1999.8764.10502505
Heck, H; Casanova, M. (2004). The implausibility of leukemia induction by formaldehyde: A critical review of the biological evidence on distant-site toxicity [Review]. Regul Toxicol Pharmacol 40: 92–106. 10.1016/j.yrtph.2004.05.001.15450713
Heck, H; Chin, TY; Schmitz, MC. (1983). Distribution of [14C] formaldehyde in rats after inhalation exposure. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 26–37). Washington, DC: Hemisphere Publishing.
Hedberg, JJ; Grafström, RC; Vondracek, M; Sarang, Z; Wärngård, L; Höög, JO. (2001). Micro-array chip analysis of carbonyl-metabolising enzymes in normal, immortalised and malignant human oral keratinocytes. Cell Mol Life Sci 58: 1719–1726. 10.1007/PL00000810.11706998
Hedberg, JJ; Höög, JO; Nilsson, JA; Xi, Z; Elfwing, A; Grafström, RC. (2000). Expression of alcohol dehydrogenase 3 in tissue and cultured cells from human oral mucosa. Am J Pathol 157: 1745–1755. 10.1016/S0002-9440(10)64811-0.11073833
Heineman, EF; Olsen, JH; Pottern, LM; Gomez, M; Raffn, E; Blair, A. (1992). Occupational risk factors for multiple myeloma among Danish men. Cancer Causes Control 3: 555–568. 10.1007/BF00052753.1420859
Hemminki, K; Kyyrönen, P; Lindbohm, ML. (1985). Spontaneous abortions and malformations in the offspring of nurses exposed to anaesthetic gases, cytostatic drugs, and other potential hazards in hospitals, based on registered information of outcome. J Epidemiol Community Health 39: 141–147. 10.1136/jech.39.2.141.3925060
Hemminki, K; Mutanen, P; Saloniemi, I; Niemi, ML; Vainio, H. (1982). Spontaneous abortions in hospital staff engaged in sterilizing instruments with chemical agents. J Occup Environ Med 285: 1461–1463.
Herbert, FA; Hessel, PA; Melenka, LS; Yoshida, K; Nakaza, M. (1994). Respiratory consequences of exposure to wood dust and formaldehyde of workers manufacturing oriented strand board. Arch Environ Health 49: 465–470. 10.1080/00039896.1994.9955002.7818289
Hess, DT; Matsumoto, A; Kim, SO; Marshall, HE; Stamler, JS. (2005). Protein S-nitrosylation: Purview and parameters [Review]. Nat Rev Mol Cell Biol 6: 150–166. 10.1038/nrm1569.15688001
Hester, SD; Barry, WT; Zou, F; Wolf, DC. (2005). Transcriptomic analysis of F344 rat nasal epithelium suggests that the lack of carcinogenic response to glutaraldehyde is due to its greater toxicity compared to formaldehyde. Toxicol Pathol 33: 415–424. 10.1080/01926230590953105.16036858
Hester, SD; Benavides, GB; Yoon, L; Morgan, KT; Zou, F; Barry, W; Wolf, DC. (2003). Formaldehyde-induced gene expression in F344 rat nasal respiratory epithelium. Toxicology 187: 13–24. 10.1016/S0300-483X(03)00008-8.12679049
Hildesheim, A; Anderson, LM; Chen, CJ; Cheng, YJ; Brinton, LA; Daly, AK; Reed, CD; Chen, IH; Caporaso, NE; Hsu, MM; Chen, JY; Idle, JR; Hoover, RN; Yang, CS; Chhabra, SK. (1997). CYP2E1 genetic polymorphisms and risk of nasopharyngeal carcinoma in Taiwan. J Natl Cancer Inst 89: 1207–1212. 10.1093/jnci/89.16.1207.9274915
Hildesheim, A; Dosemeci, M; Chan, CC; Chen, CJ; Cheng, YJ; Hsu, MM; Chen, IH; Mittl, BF; Sun, B; Levine, PH; Chen, JY; Brinton, LA; Yang, CS. (2001). Occupational exposure to wood, formaldehyde, and solvents and risk of nasopharyngeal carcinoma. Cancer Epidemiol Biomarkers Prev 10: 1145–1153.11700262
Hildesheim, A; West, S; Deveyra, E; De Guzman, MF; Jurado, A; Jones, C; Imai, J; Hinuma, Y. (1992). Herbal medicine use, Epstein-Barr virus, and risk of nasopharyngeal carcinoma. Cancer Res 52: 3048–3051.1317256
Hildesheim, A; West, S; Dosemeci, M; De Veyra, E; De Guzman, MF; Jurado, A. (1993). Nasopharyngeal carcinoma in the Philippines preliminary results from a case-control study of multiple factors. In T Tursz; JS Pagano; DV Ablashi; G de The; G Lenoir; GR Pearson (Eds.), The Epstein-Barr virus and associated diseases (pp. 743–747). Montrouge, France: John Libbey Eurotext.
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hines, RN; McCarver, DG. (2002). The ontogeny of human drug-metabolizing enzymes: Phase I oxidative enzymes [Review]. J Pharmacol Exp Ther 300: 355–360. 10.1124/jpet.300.2.355.11805191
Hisamitsu, M; Okamoto, Y; Chazono, H; Yonekura, S; Sakurai, D; Horiguchi, S; Hanazawa, T; Terada, N; Konno, A; Matsuno, Y; Todaka, E; Mori, C. (2011). The influence of environmental exposure to formaldehyde in nasal mucosa of medical students during cadaver dissection. Allergol Int 60: 373–379. 10.2332/allergolint.10-OA-0210.21593581
Ho, KF; Lee, SC; Tsai, WY. (2006a). Carbonyl compounds in the roadside environment of Hong Kong. J Hazard Mater 133: 24–29. 10.1016/j.jhazmat.2005.09.054.16297535
Ho, SSH; Yu, JZ; Chu, KW; Yeung, LL. (2006b). Carbonyl emissions from commercial cooking sources in Hong Kong. J Air Waste Manag Assoc 56: 1091–1098. 10.1080/10473289.2006.10464532.16933641
Hodgson, AT; Rudd, AF; Beal, D; Chandra, S. (2000). Volatile organic compound concentrations and emission rates in new manufactured and site-built houses. Indoor Air 10: 178–192. 10.1034/j.1600-0668.2000.010003178.x.10979199
Hohnloser, W; Osswald, B; Lingens, F. (1980). ENZYMOLOGICAL ASPECTS OF CAFFEINE DEMETHYLATION AND FORMALDEHYDE OXIDATION BY PSEUDOMONAS-PUTIDA-C1. Hoppe Seylers Z Physiol Chem 361: 1763–1766.7461603
Holland, N; Bolognesi, C; Kirsch-Volders, M; Bonassi, S; Zeiger, E; Knasmueller, S; Fenech, M. (2008). The micronucleus assay in human buccal cells as a tool for biomonitoring DNA damage: the HUMN project perspective on current status and knowledge gaps [Review]. Mutat Res Rev Mutat Res 659: 93–108. 10.1016/j.mrrev.2008.03.007.
Hollstein, MC; Peri, L; Mandard, AM; Welsh, JA; Montesano, R; Metcalf, RA; Bak, M; Harris, CC. (1991). Genetic-analysis of human esophageal tumors from 2 high-incidence geographic areas - frequent p53 base substitutions and absence of ras mutations. Cancer Res 51: 4102–4106.1855226
Holmes, BJ; Macary, PA; Noble, A; Kemeny, DM. (1997). Antigen-specific CD8+ T cells inhibit IgE responses and interleukin-4 production by CD4+ T cells. Eur J Immunol 27: 2657–2665. 10.1002/eji.1830271027.9368623
Holmstrom, M; Rynnel-Dagoo, B; Wilhelmsson, B. (1989a). Antibody production in rats after long-term exposure to formaldehyde. Toxicol Appl Pharmacol 100: 328–333. 10.1016/0041-008X(89)90318-9.2789442
Holmström, M; Wilhelmsson, B. (1988). Respiratory symptoms and pathophysiological effects of occupational exposure to formaldehyde and wood dust. Scand J Work Environ Health 14: 306–311.3201190
Holmstrom, M; Wilhelmsson, B; Hellquist, H. (1989b). Histological changes in the nasal mucosa in rats after long-term exposure to formaldehyde and wood dust. Acta Otolaryngol 108: 274–283. 10.3109/00016488909125528.2816342
Holmstrom, M; Wilhelmsson, B; Hellquist, H; Rosen, G. (1989c). Histological changes in the nasal mucosa in persons occupationally exposed to formaldehyde alone and in combination with wood dust. Acta Otolaryngol 107: 120–129. 10.3109/00016488909127488.2929309
Holness, DL; Nethercott, JR. (1989). Health status of funeral service workers exposed to formaldehyde. Arch Environ Occup Health 44: 222–228. 10.1080/00039896.1989.9935887.
Horton, AW; Tye, R; Stemmer, KL. (1963). Experimental carcinogenesis of the lung: Inhalation of gaseous formaldehyde or an aerosol of coal tar by C3H mice. J Natl Cancer Inst 30: 31–40. 10.1093/jnci/30.1.31.13964040
Horvath, EP, Jr; Anderson, H, Jr; Pierce, WE; Hanrahan, L; Wendlick, JD. (1988). Effects of formaldehyde on the mucous membranes and lungs: A study of an industrial population. JAMA 259: 701–707. 10.1001/jama.1988.03720050037020.3336189
Hosgood, HD, III; Zhang, L; Tang, X; Vermeulen, R; Hao, Z; Shen, M, in; Qiu, C; Ge, Y; Hua, M; Ji, Z; Li, S; Xiong, J, un; Reiss, B; Liu, S; Xin, KX; Azuma, M; Xie, Y; Freeman, LB; Ruan, X; Guo, W; Galvan, N, oe; Blair, A; Li, L; Huang, H; Smith, MT; Rothman, N; Lan, Q. (2013). Occupational exposure to formaldehyde and alterations in lymphocyte subsets. Am J Ind Med 56: 252–257. 10.1002/ajim.22088.22767408
Hsu, NY; Lee, CC; Wang, JY; Li, YC; Chang, HW; Chen, CY; Bornehag, CG; Wu, PC; Sundell, J; Su, HJ. (2012). Predicted risk of childhood allergy, asthma and reported symptoms using measured phthalate exposure in dust and urine. Indoor Air 22: 186–199. 10.1111/j.1600-0668.2011.00753.x.21995786
Huang, C; Liu, W; Cai, J; Wang, X; Zou, Z; Sun, CJ. (2017). Household formaldehyde exposure and its associations with dwelling characteristics, lifestyle behaviours, and childhood health outcomes in Shanghai, China. Build Environ 125: 143–152. 10.1016/j.buildenv.2017.08.042.
Hulin, M; Caillaud, D; Annesi-Maesano, I. (2010). Indoor air pollution and childhood asthma: variations between urban and rural areas. Indoor Air 20: 502–514. 10.1111/j.1600-0668.2010.00673.x.20846209
Hulsmann, AR; Dejongste, JC. (1996). Modulation of airway responsiveness by the airway epithelium in humans: Putative mechanisms. Clin Exp Allergy 26: 1236–1242.8955571
Hummel, T; Futschik, T; Frasnelli, J; Hüttenbrink, KB. (2003). Effects of olfactory function, age, and gender on trigeminally mediated sensations: a study based on the lateralization of chemosensory stimuli. Toxicol Lett 140–141: 273–280. 10.1016/s0378-4274(03)00078-x.
Hwang, G; Yoon, C; Choi, J. (2011). A case-control study: exposure assessment of VOCs and formaldehyde for asthma in children. Aerosol Air Qual Res 11: 908–914. 10.4209/aaqr.2011.05.0072.
IARC (International Agency for Research on Cancer). (1995). Wood dust and formaldehyde. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol62/index.php.
IARC (International Agency for Research on Cancer). (2006). Formaldehyde, 2-butoxyethanol and 1-tert-butoxypropan-2-ol [IARC Monograph] (pp. USD 40). (CIS/07/01141). Lyon, France. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Formaldehyde-2-Butoxyethanol-And-1--Em-Tert-Em--Butoxypropan-2-ol-2006.
IARC (International Agency for Research on Cancer). (2012). Formaldehyde [IARC Monograph]. In A review of human carcinogens: Chemical agents and related occupations (pp. 401–435). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol100F/index.php.
Ichinose, T; Miller, MG; Shibamoto, T. (1989). Gas chromatographic analysis of free and bound malonaldehyde in rat liver homogenates. Lipids 24: 895–898. 10.1007/BF02535765.2811612
ICRP (International Commission on Radiological Protection). (1994). Human respiratory tract model for radiological protection. Ann ICRP 24.
Im, H; Oh, E; Mun, J; Khim, JY; Lee, E; Kang, HS; Kim, E; Kim, H; Won, NH; Kim, YH; Jung, WW; Sul, D. (2006). Evaluation of toxicological monitoring markers using proteomic analysis in rats exposed to formaldehyde. J Proteome Res 5: 1354–1366. 10.1021/pr050437b.16739987
Imbus, HR; Tochilin, SJ. (1988). Acute effect upon pulmonary function of low level exposure to phenol-formaldehyde-resin-coated wood. AIHA J 49: 434–437. 10.1080/15298668891380033.
Ingre, C; Roos, PM; Piehl, F; Kamel, F; Fang, F. (2015). Risk factors for amyotrophic lateral sclerosis [Review]. Clinical Epidemiology 7: 181–193. 10.2147/CLEP.S37505.25709501
Ionescu, J; Marinescu, D; Tapu, V; Eskenasy, A. (1978). Experimental chronic obstructive lung disease: I. Bronchopulmonary changes induced in rabbits by prolonged exposure to formaldehyde. Morphol Embryol (Bucur) 24: 233–242.151223
IPCS (International Programme on Chemical Safety). (1989). Environmental Health Criteria 89: Formaldehyde [WHO EHC]. In Environmental Health Criteria Vol 89. (EHC 89). Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc89.htm.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Isa, KNM; Hashim, Z; Jalaludin, J; Norback, D, an; Jabbar, MA; Hashim, JH. (2020). The Impact of Exposure to Indoor Pollutants on Allergy and Lung Inflammation among School Children in Selangor, Malaysia: An Evaluation Using Factor Analysis. Aerosol Air Qual Res 20: 2371–2383. 10.4209/aaqr.2020.03.0128.
Ito, K; Sakamoto, T; Hayashi, Y; Morishita, M; Shibata, E; Sakai, K; Takeuchi, Y; Torii, S. (1996). Role of tachykinin and bradykinin receptors and mast cells in gaseous formaldehyde-induced airway microvascular leakage in rats. Eur J Pharmacol 307: 291–298. 10.1016/0014-2999(96)00285-3.8836617
Jakab, GJ. (1992). Relationship between carbon black particulate-bound formaldehyde, pulmonary antibacterial defenses, and alveolar macrophage phagocytosis. Inhal Toxicol 4: 325–342. 10.3109/08958379209145312.
Jakab, GJ; Risby, TH; Hemenway, DR. (1992). Use of physical chemistry and in vivo exposure to investigate the toxicity of formaldehyde bound to carbonaceous particles in the murine lung (pp. 1–39, discussion 41-39). (ISSN 1041-5505 EISSN 2688-6855 NTIS/02982016_2). Cambridge, MA: Health Effects Institute.
Jakab, MG; Klupp, T; Besenyei, K; Biro, A; Major, J; Tompa, A. (2010). Formaldehyde-induced chromosomal aberrations and apoptosis in peripheral blood lymphocytes of personnel working in pathology departments. Mutat Res 698: 11–17. 10.1016/j.mrgentox.2010.02.015.20193773
Jakobsson, K; Mikoczy, Z; Skerfving, S. (1997). Deaths and tumours among workers grinding stainless steel: a follow up. Occup Environ Med 54: 825–829. 10.1136/oem.54.11.825.9538356
Jakopovic, M; Thomas, A; Balasubramaniam, S; Schrump, D; Giaccone, G; Bates, SE. (2013). Targeting the epigenome in lung cancer: expanding approaches to epigenetic therapy [Review]. 3: 261. 10.3389/fonc.2013.00261.
Jarnstrom, H; Saarela, K; Kalliokoski, P; Pasanen, AL. (2006). Reference values for indoor air pollutant concentrations in new, residential buildings in Finland. Atmos Environ 40: 7178–7191. 10.1016/j.atmosenv.2006.06.021.
Jenkins, MA; Clarke, JR; Carlin, JB; Robertson, CF; Hopper, JL; Dalton, MF; Holst, DP; Choi, K; Giles, GG. (1996). Validation of questionnaire and bronchial hyperresponsiveness against respiratory physician assessment in the diagnosis of asthma. Int J Epidemiol 25: 609–616. 10.1093/ije/25.3.609.8671563
Jensen, DE; Belka, GK; Du Bois, GC. (1998). S-Nitrosoglutathione is a substrate for rat alcohol dehydrogenase class III isoenzyme. Biochem J 331: 659–668. 10.1042/bj3310659.9531510
Ji, Z; Li, X; Fromowitz, M; Mutter-Rottmayer, E; Tung, J; Smith, MT; Zhang, L. (2014). Formaldehyde induces micronuclei in mouse erythropoietic cells and suppresses the expansion of human erythroid progenitor cells. Toxicol Lett 224: 233–239. 10.1016/j.toxlet.2013.10.028.24188930
Jia, X; Jia, Q; Zhang, Z; Gao, W; Zhang, X; Niu, Y; Meng, T; Feng, B; Duan, H; Ye, M; Dai, Y; Jia, Z; Zheng, Y. (2014). Effects of formaldehyde on lymphocyte subsets and cytokines in the peripheral blood of exposed workers. PLoS ONE 9: e104069. 10.1371/journal.pone.0104069.25157974
Jiang, S; Yu, L; Cheng, J; Leng, S; Dai, Y; Zhang, Y; Niu, Y; Yan, H; Qu, W; Zhang, C; Zhang, K; Yang, R; Zhou, L; Zheng, Y. (2010). Genomic damages in peripheral blood lymphocytes and association with polymorphisms of three glutathione S-transferases in workers exposed to formaldehyde. Mutat Res 695: 9–15. 10.1016/j.mrgentox.2009.09.011.19818869
Jinot, J; Beane-Freeman, L. (2014). Personal communication Jennifer Jinot and Laura Beane-Freeman.
Joffe, M; Vilard, L; Li, Z; Powman, R; Vessey, M. (1993). Long-term recall of time-to-pregnancy. Fertil Steril 60: 99–104. 10.1016/s0015-0282(16)56044-0.8513966
Joffe, M; Villard, L; Li, ZM; Plowman, R; Vessey, M. (1995). A time to pregnancy questionnaire designed for long-term recall - Validity in Oxford, England. J Epidemiol Community Health 49: 314–319. 10.1136/jech.49.3.314.7629471
John, EM; Savitz, DA; Shy, CM. (1994). Spontaneous abortions among cosmetologists. Epidemiology 5: 147–155. 10.1097/00001648-199403000-00004.8172989
Juchau, MR; Lee, OP; Fantel, AG. (1992). Xenobiotic biotransformation/bioactivation in organogenesis-stage conceptual tissues: implications for embryotoxicity and teratogenesis [Review]. Drug Metab Rev 24: 195–238. 10.3109/03602539208996293.1576936
Jung, W; Kim, E; Lee, E; Yun, H; Ju, H; Jeong, M; Hwang, K; Sul, D; Kang, H. (2007). Formaldehyde exposure induces airway inflammation by increasing eosinophil infiltrations through the regulation of reactive oxygen species production. Environ Toxicol Pharmacol 24: 174–182. 10.1016/j.etap.2007.05.001.21783807
Jurvelin, J; Vartiainen, M; Jantunen, M; Pasanen, P. (2001). Personal exposure levels and microenvironmental concentrations of formaldehyde and acetaldehyde in the Helsinki metropolitan area, Finland. J Air Waste Manag Assoc 51: 17–24. 10.1080/10473289.2001.10464251.11218421
Kamata, E; Nakadate, M; Uchida, O; Ogawa, Y; Kaneko, T; Kurokawa, Y. (1996). Effects of formaldehyde vapor on the nasal cavity and lungs of F-344 rats. J Environ Pathol Toxicol Oncol 15: 1–8.9037259
Kamata, E; Nakadate, M; Uchida, O; Ogawa, Y; Suzuki, S; Kaneko, T; Saito, M; Kurokawa, Y. (1997). Results of a 28-month chronic inhalation toxicity study of formaldehyde in male Fisher-344 rats. J Toxicol Sci 22: 239–254.
Kane, LE; Alarie, T. (1977). Sensory irritation to formaldehyde during single and repeated exposures in mice [Abstract]. Toxicol Appl Pharmacol 41: 180–181.
Kaplan, S. (2012). [Email to Andrew Kraft regarding formaldehyde neurodevelopmental studies].
Kaplan, S. (2014). [Email with Andrew Kraft regarding follow-up on Sarsilmaz et al., 2007 and Aslan et al., 2006].
Kar, S; Krishnan, A; Shivkumar, PV. (2012). Pregnancy and skin. Journal of Obstetrics and Gynaecology of India 268–275. 10.1007/s13224-012-0179-z.23730028
Karamouzis, MV; Konstantinopoulos, PA; Papavassiliou, AG. (2007). The activator protein-1 transcription factor in respiratory epithelium carcinogenesis [Review]. Mol Cancer Res 5: 109–120. 10.1158/1541-7786.MCR-06-0311.17314269
Kashiba, H; Ueda, Y; Senba, E. (1997). Systemic capsaicin in the adult rat differentially affects gene expression for neuropeptides and neurotrophin receptors in primary sensory neurons. Neuroscience 76: 299–312.8971780
Katsnelson, BA; Degtyareva, TD; Privalova, LI; Minigaliyeva, IA; Slyshkina, TV; Ryzhov, VV; Beresneva, OY, u. (2013). Attenuation of subchronic formaldehyde inhalation toxicity with oral administration of glutamate, glycine and methionine. Toxicol Lett 220: 181–186. 10.1016/j.toxlet.2013.04.024.23660335
Keller, DA; Heck, H; Randall, HW; Morgan, KT. (1990). Histochemical localization of formaldehyde dehydrogenase in the rat. Toxicol Appl Pharmacol 106: 311–326. 10.1016/0041-008x(90)90250-x.2256119
Kepler, GM; Richardson, RB; Morgan, KT; Kimbell, JS. (1998). Computer simulation of inspiratory nasal airflow and inhaled gas uptake in a rhesus monkey. Toxicol Appl Pharmacol 150: 1–11. 10.1006/taap.1997.8350.9630447
Kerns, WD; Pavkov, KL; Donofrio, DJ; Gralla, EJ; Swenberg, JA. (1983). Carcinogenicity of formaldehyde in rats and mice after long-term inhalation exposure. Cancer Res 43: 4382–4392.6871871
Khamgaonkar, MB; Fulare, MB. (1991). Pulmonary effects of formaldehyde exposure--an environmental-epidemiological study. Indian J Chest Dis Allied Sci 33: 9–13.1791022
Kilburn, KH. (2000). Indoor air effects after building renovation and in manufactured homes. Am J Med Sci 320: 249–254. 10.1097/00000441-200010000-00005.11061350
Kilburn, KH; Warshaw, R; Boylen, CT; Johnson, SJ; Seidman, B; Sinclair, R; Takaro, T. (1985). Pulmonary and neurobehavioral effects of formaldehyde exposure. Arch Environ Health 40: 254–260. 10.1080/00039896.1985.10545928.4062359
Kilburn, KH; Warshaw, R; Thornton, JC. (1987). Formaldehyde impairs memory, equilibrium, and dexterity in histology technicians: Effects which persist for days after exposure. Arch Environ Occup Health 42: 117–120. 10.1080/00039896.1987.9935806.
Kilburn, KH; Warshaw, R; Thornton, JC. (1989a). Pulmonary function in histology technicians compared with women from Michigan: effects of chronic low dose formaldehyde on a national sample of women. Br J Ind Med 46: 468–472. 10.1136/oem.46.7.468.2765419
Kilburn, KH; Warshaw, R; Thornton, JC; Husmark, I. (1989b). An examination of factors that could affect choice reaction time in histology technicians. Am J Ind Med 15: 679–686. 10.1002/ajim.4700150607.2750743
Kilburn, KH; Warshaw, RH. (1992). Neurobehavioral effects of formaldehyde and solvents on histology technicians: Repeated testing across time. Environ Res 58: 134–146. 10.1016/S0013-9351(05)80210-5.1511669
Kim, CW; Song, JS; Ahn, YS; Park, SH; Park, JW; Noh, JH; Hong, CS. (2001). Occupational asthma due to formaldehyde. Yonsei Med J 42: 440–445. 10.3349/ymj.2001.42.4.440.11519088
Kim, EM; Lee, HY; Lee, EH; Lee, KM; Park, M; Ji, KY; Jang, JH; Jeong, YH; Lee, KH; Yoon, IJ; Kim, SM; Jeong, MJ; Kim, KD; Kang, HS. (2013a). Formaldehyde exposure impairs the function and differentiation of NK cells. Toxicol Lett 223: 154–161. 10.1016/j.toxlet.2013.09.008.24060340
Kim, H; Kim, YD; Cho, SH. (1999). Formaldehyde exposure levels and serum antibodies to formaldehyde-human serum albumin of Korean medical students. Arch Environ Health 54: 115–118. 10.1080/00039899909602245.10094289
Kim, H; Levin, L; Lemasters, GK; Villareal, M; Evans, S; Lockey, JE; Hershey, GKK; Bernstein, DI. (2012). Validating childhood symptoms with physician-diagnosed allergic rhinitis. Ann Allergy Asthma Immunol 108: 228–231. 10.1016/j.anai.2012.02.004.22469440
Kim, JL; Elfman, L; Wieslander, G; Ferm, M; Torén, K; Norbäck, D. (2011). Respiratory health among Korean pupils in relation to home, school and outdoor environment. J Korean Med Sci 26: 166–173. 10.3346/jkms.2011.26.2.166.21286005
Kim, JY; Jeong, MS; Park, KY; Seo, SJ. (2013b). Aggravation of atopic dermatitis-like symptoms by consecutive low concentration of formaldehyde exposure in NC/Nga mice [Letter]. Exp Dermatol 22: 219–221. 10.1111/exd.12092.23387407
Kim, Y; Jekarl, DW; Kim, J; Kwon, A; Choi, H; Lee, S; Kim, YJ; Kim, HJ; Kim, Y; Oh, IH; Kim, M. (2015). Genetic and epigenetic alterations of bone marrow stromal cells in myelodysplastic syndrome and acute myeloid leukemia patients. Stem Cell Research 14: 177–184. 10.1016/j.scr.2015.01.004.25665922
Kimbell, JS; Godo, MN; Gross, EA; Joyner, DR; Richardson, RB; Morgan, KT. (1997a). Computer simulation of inspiratory airflow in all regions of the F344 rat nasal passages. Toxicol Appl Pharmacol 145: 388–398. 10.1006/taap.1997.8206.9266813
Kimbell, JS; Gross, EA; Joyner, DR; Godo, MN; Morgan, KT. (1993). Application of computational fluid dynamics to regional dosimetry of inhaled chemicals in the upper respiratory tract of the rat. Toxicol Appl Pharmacol 121: 253–263. 10.1006/taap.1993.1152.8346542
Kimbell, JS; Gross, EA; Richardson, RB; Conolly, RB; Morgan, KT. (1997b). Correlation of regional formaldehyde flux predictions with the distribution of formaldehyde-induced squamous metaplasia in F344 rat nasal passages. Mutat Res 380: 143–154. 10.1016/S0027-5107(97)00132-2.9385395
Kimbell, JS; Overton, JH; Subramaniam, RP; Schlosser, PM; Morgan, KT; Conolly, RB; Miller, FJ. (2001a). Dosimetry modeling of inhaled formaldehyde: Binning nasal flux predictions for quantitative risk assessment. Toxicol Sci 64: 111–121.11606807
Kimbell, JS; Subramaniam, RP. (2001). Use of computational fluid dynamics models for dosimetry of inhaled gases in the nasal passages [Review]. Inhal Toxicol 13: 325–334. 10.1080/08958370120442.11295865
Kimbell, JS; Subramaniam, RP; Gross, EA; Schlosser, PM; Morgan, KT. (2001b). Dosimetry modeling of inhaled formaldehyde: comparisons of local flux predictions in the rat, monkey, and human nasal passages. Toxicol Sci 64: 100–110.11606806
Kimura, R; Kimoto, I; Takeda, M; Miyake, M; Sakamoto, T. (2010). Alteration in airway microvascular leakage induced by sensorineural stimulation in rats exposed to inhaled formaldehyde. Toxicol Lett 199: 254–260. 10.1016/j.toxlet.2010.09.007.20849939
Kirsch-Volders, M; Bonassi, S; Knasmueller, S; Holland, N; Bolognesi, C; Fenech, MF. (2014). Commentary: Critical questions, misconceptions and a road map for improving the use of the lymphocyte cytokinesis-block micronucleus assay for in vivo biomonitoring of human exposure to genotoxic chemicals-A HUMN project perspective. Mutat Res Rev Mutat Res 759: 49–58. 10.1016/j.mrrev.2013.12.001.24412600
Kitaev, EM; Savchenko, ON; Lovchikov, VA; Altukhov, VV; Vishnyakov, YS. (1984). Razvitie zarodyshey i nekotorye pokazateli reproductivnoy funktsii u krys posle ingalyatsionnogo vozdeystviya formal’degida do oplodotvoreniya [Akush Ginekol 10: 49–52.
Kleinnijenhuis, AJ; Staal, YC; Duistermaat, E; Engel, R; Woutersen, RA. (2013). The determination of exogenous formaldehyde in blood of rats during and after inhalation exposure. Food Chem Toxicol 52: 105–112. 10.1016/j.fct.2012.11.008.23159914
Kligerman, AD; Phelps, MC; Erexson, GL. (1984). Cytogenetic analysis of lymphocytes from rats following formaldehyde inhalation. Toxicol Lett 21: 241–246. 10.1016/0378-4274(84)90079-1.6740713
Klonisch, T; Fowler, PA; Hombach-Klonisch, S. (2004). Molecular and genetic regulation of testis descent and external genitalia development [Review]. Dev Biol 270: 1–18. 10.1016/j.ydbio.2004.02.018.15136137
Kominsky, JR; Stroman, RE. (1977). Health Hazard Evaluation Determination, Report No. HHE-77-15-421, Leed and Northrup Corporation, Expendable Devices Division Ellwood City, Pennsylvania (pp. 77–15). (NIOSH/00074930). Kominsky, JR; Stroman, RE. https://www.cdc.gov/niosh/hhe/reports/pdfs/77-15-421.pdf.
Kopf, M; Le Gros, G; Bachmann, M; Lamers, MC; Bluethmann, H; Köhler, G. (1993). Disruption of the murine IL-4 gene blocks Th2 cytokine responses. Nature 362: 245–248. 10.1038/362245a0.8384701
Korhonen, K; Liukkonen, T; Ahrens, W; Astrakianakis, G; Boffetta, P; Burdorf, A; Heederik, D; Kauppinen, T; Kogevinas, M; Osvoll, P; Rix, BA; Saalo, A; Sunyer, J; Szadkowska-Stanczyk, I; Teschke, K; Westberg, H; Widerkiewicz, K. (2004). Occupational exposure to chemical agents in the paper industry. Int Arch Occup Environ Health 77: 451–460. 10.1007/s00420-004-0530-5.15368059
Krakowiak, A; Górski, P; Pazdrak, K; Ruta, U. (1998). Airway response to formaldehyde inhalation in asthmatic subjects with suspected respiratory formaldehyde sensitization. Am J Ind Med 33: 274–281. 10.1002/(SICI)1097-0274(199803)33:3<274::AID-AJIM9>3.0.CO;2-W.9481426
Krewski, D; Crump, KS; Farmer, J; Gaylor, DW; Howe, R; Portier, C; Salsburg, D; Sielken, RL; Van Ryzin, J. (1983). A comparison of statistical methods for low dose extrapolation utilizing time-to-tumour data. Fundam Appl Toxicol 3: 140–160. 10.1016/S0272-0590(83)80075-X.6884628
Kriebel, D; Myers, D; Cheng, M; Woskie, S; Cocanour, B. (2001). Short-term effects of formaldehyde on peak expiratory flow and irritant symptoms. Arch Environ Health 56: 11–18. 10.1080/00039890109604049.11256851
Kriebel, D; Sama, SR; Cocanour, B. (1993). Reversible pulmonary responses to formaldehyde. A study of clinical anatomy students. Am Rev Respir Dis 148: 1509–1515. 10.1164/ajrccm/148.6_Pt_1.1509.8256892
Krzyzanowski, M; Quackenboss, JJ; Lebowitz, MD. (1990). Chronic respiratory effects of indoor formaldehyde exposure. Environ Res 52: 117–125. 10.1016/S0013-9351(05)80247-6.2394203
Ku, RH; Billings, RE. (1984). Relationships between formaldehyde metabolism and toxicity and glutathione concentrations in isolated rat hepatocytes. Chem Biol Interact 51: 25–36. 10.1016/0009-2797(84)90017-6.6744474
Kuehner, S; Holzmann, K; Speit, G. (2013). Characterization of formaldehyde’s genotoxic mode of action by gene expression analysis in TK6 cells. Arch Toxicol 87: 1999–2012. 10.1007/s00204-013-1060-2.23649840
Kuehner, S; Schlaier, M; Schwarz, K; Speit, G. (2012). Analysis of leukemia-specific aneuploidies in cultured myeloid progenitor cells in the absence and presence of formaldehyde exposure. Toxicol Sci 128: 72–78. 10.1093/toxsci/kfs126.22472192
Kulle, TJ. (1993). Acute odor and irritation response in healthy nonsmokers with formaldehyde exposure. Inhal Toxicol 5: 323–332. 10.3109/08958379308998389.
Kulle, TJ; Cooper, GP. (1975). Effects of formaldehyde and ozone on the trigeminal nasal sensory system. Arch Environ Occup Health 30: 237–243.
Kulle, TJ; Sauder, LR; Hebel, JR; Green, DJ; Chatham, MD. (1987). Formaldehyde dose-response in healthy nonsmokers. J Air Pollut Control Assoc 37: 919–924. 10.1080/08940630.1987.10466285.
Kum, C; Kiral, F; Sekkin, S; Seyrek, K; Boyacioglu, M. (2007). Effects of xylene and formaldehyde inhalations on oxidative stress in adult and developing rats livers. Exp Anim 56: 35–42. 10.1538/expanim.56.35.17283889
Kumar, H; Jain, R; Douglas, RG; Tawhai, MH. (2016). Airflow in the human nasal passage and sinuses of chronic rhinosinusitis subjects. PLoS ONE 11: e0156379. 10.1371/journal.pone.0156379.27249219
Kumari, A; Owen, N; Juarez, E; Mccullough, AK. (2015). BLM protein mitigates formaldehyde-induced genomic instability. DNA Repair 28: 73–82. 10.1016/j.dnarep.2015.02.010.25770783
Kunkler, PE; Ballard, CJ; Oxford, GS; Hurley, JH. (2011). TRPA1 receptors mediate environmental irritant-induced meningeal vasodilatation. Pain 152: 38–44. 10.1016/j.pain.2010.08.021.21075522
Kuo, HW; Jian, GJ; Chen, CL; Liu, CS; Lai, JS. (1997). White blood cell count as an indicator of formaldehyde exposure. Bull Environ Contam Toxicol 59: 261–267. 10.1007/s001289900473.9211697
Kuper, CF; van Oostrum, L; Ma-Hock, L; Durrer, S; Woutersen, RA. (2011). Hyperplasia of the lymphoepithelium of NALT in rats but not in mice upon 28-day exposure to 15 ppm formaldehyde vapor. Exp Toxicol Pathol 63: 25–32. 10.1016/j.etp.2009.09.004.19783130
Labrèche, F; Forest, J; Trottier, M; Lalonde, M; Simard, R. (2003). Characterization of chemical exposures in hairdressing salons. Appl Occup Environ Hyg 18: 1014–1021. 10.1080/10473220390244667.14612298
Ladeira, C; Viegas, S; Carolino, E; Gomes, MC; Brito, M. (2013). The influence of genetic polymorphisms in XRCC3 and ADH5 genes on the frequency of genotoxicity biomarkers in workers exposed to formaldehyde. Environ Mol Mutagen 54: 213–221. 10.1002/em.21755.23355119
Ladeira, C; Viegas, S; Carolino, E; Prista, J; Gomes, MC; Brito, M. (2011). Genotoxicity biomarkers in occupational exposure to formaldehyde--the case of histopathology laboratories. Mutat Res 721: 15–20. 10.1016/j.mrgentox.2010.11.015.21256246
Laforest, L; Luce, D; Goldberg, P; Bégin, D; Gérin, M; Demers, PA; Brugère, J; Leclerc, A. (2000). Laryngeal and hypopharyngeal cancers and occupational exposure to formaldehyde and various dusts: A case-control study in France. Occup Environ Med 57: 767–773. 10.1136/oem.57.11.767.11024201
Lai, Y; Yu, R; Hartwell, HJ; Moeller, BC; Bodnar, WM; Swenberg, JA. (2016). Measurement of Endogenous versus Exogenous Formaldehyde-Induced DNA-Protein Crosslinks in Animal Tissues by Stable Isotope Labeling and Ultrasensitive Mass Spectrometry. Cancer Res 76: 2652–2661. 10.1158/0008-5472.CAN-15-2527.26984759
Lajoie, P; Aubin, D; Gingras, V; Daigneault, P; Ducharme, F; Gauvin, FD; Fugler, D; Leclerc, JM; Won, D; Won, D; Courteau, M; Gingras, S; Héroux, MÈ; Yang, W; Schleibinger, H. (2014). The ivaire project - a randomized controlled study of the impact of ventilation on indoor air quality and the respiratory symptoms of asthmatic children in single family homes. Indoor Air 25: 582–597. 10.1111/ina.12181.
Lakwijk, N; Van Strien, RT; Doekes, G; Brunekreef, B; Gerritsen, J. (1998). Validation of a screening questionnaire for atopy with serum IgE tests in a population of pregnant Dutch women. Clin Exp Allergy 28: 454–458. 10.1046/j.1365-2222.1998.00254.x.9641572
Lam, CW; Casanova, M; Heck, H. (1985). Depletion of nasal mucosal glutathione by acrolein and enhancement of formaldehyde-induced DNA-protein cross-linking by simultaneous exposure to acrolein. Arch Toxicol 58: 67–71. 10.1007/bf00348311.4091658
Lan, Q; Smith, MT; Tang, X; Guo, W; Vermeulen, R; Ji, Z; Hu, W; Hubbard, AE; Min, S; Mchale, CM; Qiu, C; Liu, S; Reiss, B; Beane Freeman, L; Blair, A; Ge, Y; Xiong, J; Li, L; Rappaport, SM; Huang, H; Rothman, N; Zhang, L. (2015). Chromosome-wide aneuploidy study (CWAS) of cultured circulating myeloid progenitor cells from workers occupationally exposed to formaldehyde. Carcinogenesis 36: 160–167. 10.1093/carcin/bgu229.25391402
Lang, I; Bruckner, T; Triebig, G. (2008). Formaldehyde and chemosensory irritation in humans: A controlled human exposure study. Regul Toxicol Pharmacol 50: 23–36. 10.1016/j.yrtph.2007.08.012.17942205
Langevin, F; Crossan, GP; Rosado, IV; Arends, MJ; Patel, KJ. (2011). Fancd2 counteracts the toxic effects of naturally produced aldehydes in mice. Nature 475: 53–58. 10.1038/nature10192.21734703
Larsen, ST; Wolkoff, P; Hammer, M; Kofoed-Sørensen, V; Clausen, PA; Nielsen, GD. (2013). Acute airway effects of airborne formaldehyde in sensitized and non-sensitized mice housed in a dry or humid environment. Toxicol Appl Pharmacol 268: 294–299. 10.1016/j.taap.2013.02.006.23462310
Lazenby, V; Hinwood, A; Callan, A; Franklin, P. (2012). Formaldehyde personal exposure measurements and time weighted exposure estimates in children. Chemosphere 88: 966–973. 10.1016/j.chemosphere.2012.03.029.22516208
Lebowitz, MD; Krzyzanowski, M; Quackenboss, JJ; Orourke, MK. (1997). Diurnal variation of PEF and its use in epidemiological studies. Eur Respir J 10: S49–S56.
Leclerc, A; Luce, D; Demers, PA; Boffetta, P; Kogevinas, M; Belli, S; Bolm-Audorff, U; Brinton, LA; Colin, D; Comba, P; Gerin, M; Hardell, L; Hayes, RB; Magnani, C; Merler, E; Morcet, JF; Preston-Martin, S; Vaughan, TL; Zheng, W. (1997). Sinonasal cancer and occupation. Results from the reanalysis of twelve case-control studies. Am J Ind Med 31: 153–165. 10.1002/(sici)1097-0274(199702)31:2<153::aid-ajim4>3.0.co;2-0.9028431
Leclerc, A; Martinez Cortes, M; Gérin, M; Luce, D; Brugère, J. (1994). Sinonasal cancer and wood dust exposure: Results from a case-control study. Am J Epidemiol 140: 340–349. 10.1093/oxfordjournals.aje.a117256.8059769
Lee, HK; Alarie, Y; Karol, MH. (1984). Induction of formaldehyde sensitivity in guinea pigs. Toxicol Appl Pharmacol 75: 147–155. 10.1016/0041-008X(84)90085-1.6464018
Lee, JT; Ko, CY. (2005). Has survival improved for nasopharyngeal carcinoma in the United States? Otolaryngol Head Neck Surg 132: 303–308. 10.1016/j.otohns.2004.09.018.15692545
Lee, PN; Fry, JS. (2010). Systematic review of the evidence relating FEV1 decline to giving up smoking [Review]. BMC Med 8: 84. 10.1186/1741-7015-8-84.21156048
Leikauf, GD. (1992). Mechanisms of aldehyde-induced bronchial reactivity: Role of airway epithelium (pp. 1–35). (Research Report Number 49). Boston, MA: Health Effects Institute.
Leng, J; Liu, CW; Hartwell, HJ; Yu, R; Lai, Y; Bodnar, WM; Lu, K; Swenberg, JA. (2019). Evaluation of inhaled low-dose formaldehyde-induced DNA adducts and DNA-protein cross-links by liquid chromatography-tandem mass spectrometry. Arch Toxicol 93: 763–773. 10.1007/s00204-019-02393-x.30701286
Lessard, M; Hélias, C; Struski, S; Perrusson, N; Uettwiller, F; Mozziconacci, MJ; Lafage-Pochitaloff, M; Dastugue, N; Terré, C; Brizard, F; Cornillet-Lefebvre, P; Mugneret, F; Barin, C; Herry, A; Luquet, I; Desangles, F; Michaux, L; Verellen-Dumoulin, C; Perrot, C; Van Den Akker, J; Lespinasse, J; Eclache, V; Berger, R; Hématologique, GFdC. (2007). Fluorescence in situ hybridization analysis of 110 hematopoietic disorders with chromosome 5 abnormalities: Do de novo and therapy-related myelodysplastic syndrome-acute myeloid leukemia actually differ? Cancer Genet Cytogenet 176: 1–21. 10.1016/j.cancergencyto.2007.01.013.17574959
Lévesque, JP; Winkler, IG; Larsen, SR; Rasko, JE. (2007). Mobilization of bone marrow-derived progenitors [Review]. Handb Exp Pharmacol 3–36. 10.1007/978-3-540-68976-8_1.
Levine, RJ; Andjelkovich, DA; Shaw, LK. (1984a). The mortality of Ontario (Canada) undertakers and a review of a formaldehyde-related mortality studies. J Occup Med 26: 740–746.6491780
Levine, RJ; Dalcorso, RD; Blunden, PB; Battigelli, MC. (1984b). The effects of occupational exposure on the respiratory health of West Virginia morticians. J Occup Med 26: 91–98.6707776
Li, AM; Fung, CK; Yu, IT; Goggins, WB; Chan, GY; Chan, CK; Lau, AP; Leung, JO. (2019). Associations of wheeze during the first 18 months of life with indoor nitrogen dioxide, formaldehyde, and family history of asthma: a prospective cohort study. Hong Kong Med J 25 Suppl 3: 20–23.30792368
Li, B; Huang, G; Zhang, X; Li, R; Wang, J; Dong, Z; He, Z. (2013a). Increased phosphorylation of histone H3 at serine 10 is involved in Epstein-Barr virus latent membrane protein-1-induced carcinogenesis of nasopharyngeal carcinoma. BMC Cancer 13: 124. 10.1186/1471-2407-13-124.23496845
Li, Q; Mei, Q; Huyan, T; Xie, L; Che, S; Yang, H; Zhang, M; Huang, Q. (2013b). Effects of formaldehyde exposure on human NK cells in vitro. Environ Toxicol Pharmacol 36: 948–955. 10.1016/j.etap.2013.08.005.24035925
Li, T; Chen, JX; Fu, XP; Yang, S; Zhang, Z; Chen, KH; Li, Y. (2011). microRNA expression profiling of nasopharyngeal carcinoma. Oncol Rep 25: 1353–1363. 10.3892/or.2011.1204.21373758
Li, W; Ray, RM; Gao, DL; Fitzgibbons, ED; Seixas, NS; Camp, JE; Wernli, KJ; Astrakianakis, G; Feng, Z; Thomas, DB; Checkoway, H. (2006). Occupational risk factors for nasopharyngeal cancer among female textile workers in Shanghai, China. Occup Environ Med 63: 39–44. 10.1136/oem.2005.021709.16361404
Li, Y; Song, Z; Ding, Y; Xin, Y, e; Wu, T; Su, T, ao; He, R; Tai, F; Lian, Z. (2016). Effects of formaldehyde exposure on anxiety-like and depression-like behavior, cognition, central levels of glucocorticoid receptor and tyrosine hydroxylase in mice. Chemosphere 144: 2004–2012. 10.1016/j.chemosphere.2015.10.102.26551198
Li, Z; Chen, L; Qin, Z. (2009). Paradoxical roles of IL-4 in tumor immunity [Review]. Cell Mol Immunol 6: 415–422. 10.1038/cmi.2009.53.20003817
Liao, S; Jiang, L; Zhang, X. (2010). [Effects of inhaled formaldehyde on learning and memory and expression of CaMK II in hippocampus of Wistar rats of different ages]. Chongqing Yike Daxue Xuebao 35: 342–344.
LICM (Lithium Ion Cell Manufacturers’ Coalition). (2008). Effect of inhaled formaldehyde on learning and memory of mice. Indoor Air 18: 77–83. 10.1111/j.1600-0668.2008.00524.x.18333987
Lim, SK; Choi, H; Park, MJ; Kim, DI; Kim, JC; Kim, GY; Jeong, SY; Rodionov, RN; Han, HJ; Yoon, KC; Park, SH. (2013). The ER stress-mediated decrease in DDAH1 expression is involved in formaldehyde-induced apoptosis in lung epithelial cells. Food Chem Toxicol 62: 763–769. 10.1016/j.fct.2013.10.014.24140967
Lima, LF; Murta, GL; Bandeira, AC; Nardeli, CR; Lima, WG; Bezerra, FS. (2015). Short-term exposure to formaldehyde promotes oxidative damage and inflammation in the trachea and diaphragm muscle of adult rats. Ann Anat 202: 45–51. 10.1016/j.aanat.2015.08.003.26342159
Lin, D; Guo, Y; Yi, J; Kuang, D, an; Li, X; Deng, H; Huang, K, un; Guan, L, ei; He, Y; Zhang, X; Hu, D, ie; Zhang, Z; Zheng, H; Zhang, X; Mchale, CM; Zhang, L; Wu, T. (2013). Occupational exposure to formaldehyde and genetic damage in the peripheral blood lymphocytes of plywood workers. J Occup Health 55: 284–291. 10.1539/joh.12-0288-OA.23648472
Lindahl, T. (1993). INSTABILITY AND DECAY OF THE PRIMARY STRUCTURE OF DNA. Nature 362: 709–715.8469282
Lindbohm, ML; Hemminki, K. (1988). Nationwide data base on medically diagnosed spontaneous abortions in Finland. Int J Epidemiol 17: 568–573. 10.1093/ije/17.3.568.3209336
Lindbohm, ML; Hemminki, K; Bonhomme, MG; Anttila, A; Rantala, K; Heikkila, P; Rosenberg, MJ. (1991). Effects of paternal occupational exposure on spontaneous abortions. Am J Public Health 81: 1029–1033. 10.2105/ajph.81.8.1029.1853994
Lippman, SM; Peters, EJ; Wargovich, MJ; Stadnyk, AN; Dixon, DO; Dekmezian, RH; Loewy, JW; Morice, RC; Cunningham, JE; Hong, WK. (1990). Bronchial micronuclei as a marker of an early stage of carcinogenesis in the human tracheobronchial epithelium. Int J Cancer 45: 811–815. 10.1002/ijc.2910450503.2335384
Liteplo, RG; Meek, ME. (2003). Inhaled formaldehyde: Exposure estimation, hazard characterization, and exposure-response analysis [Review]. J Toxicol Environ Health B Crit Rev 6: 85–114. 10.1080/10937400306480.12587255
Liu, D; Zheng, Y; Li, B; Yao, H; Li, R; Zhang, Y; Yang, X. (2011a). Adjuvant effects of gaseous formaldehyde on the hyper-responsiveness and inflammation in a mouse asthma model immunized by ovalbumin. J Immunotoxicol 8: 305–314. 10.3109/1547691X.2011.600738.21854218
Liu, KS; Huang, FY; Hayward, SB; Wesolowski, J; Sexton, K. (1991). Irritant effects of formaldehyde exposure in mobile homes. Environ Health Perspect 94: 91–94. 10.2307/3431298.1954947
Liu, Q; Yang, L; Gong, C; Tao, G; Huang, H; Liu, J; Zhang, H; Wu, D; Xia, B; Hu, G; Wang, K; Zhuang, Z. (2011b). Effects of long-term low-dose formaldehyde exposure on global genomic hypomethylation in 16HBE cells. Toxicol Lett 205: 235–240. 10.1016/j.toxlet.2011.05.1039.21745553
Liu, QB; Wang, W; Jing, W. (2018). Indoor air pollution aggravates asthma in Chinese children and induces the changes in serum level of miR-155. Int J Environ Health Res 29: 1–9. 10.1080/09603123.2018.1506569.30084259
Liu, W; Zhang, J; Hashim, JH; Jalaludin, J; Hashim, Z; Goldstein, BD. (2003). Mosquito coil emissions and health implications. Environ Health Perspect 111: 1454–1460. 10.1289/ehp.6286.12948883
Liu, Y, i; Ye, Z; Luo, H; Sun, M; Li, M, i; Fan, D; Chui, D. (2009). Inhalative formaldehyde exposure enhances aggressive behavior and disturbs monoamines in frontal cortex synaptosome of male rats. Neurosci Lett 464: 113–116. 10.1016/j.neulet.2009.06.037.19545605
Liu, Y; Ye, Z; Yang, H; Zhou, L; Fan, D; He, S; Chui, D. (2010). Disturbances of soluble N-ethylmaleimide-sensitive factor attachment proteins in hippocampal synaptosomes contribute to cognitive impairment after repetitive formaldehyde inhalation in male rats. Neuroscience 169: 1248–1254. 10.1016/j.neuroscience.2010.05.061.20609425
Liu, Y; Yu, D; Xiao, S. (2017). Effects of chronic exposure to Formaldehyde on micronucleus rate of bone marrow cells in male mice. J Pak Med Assoc 67: 933–935.28585597
Llorente, JL; López, F; Suárez, C; Hermsen, MA. (2014). Sinonasal carcinoma: clinical, pathological, genetic and therapeutic advances [Review]. Nat Rev Clin Oncol 11: 460–472. 10.1038/nrclinonc.2014.97.24935016
Lo Celso, C; Scadden, DT. (2011). The haematopoietic stem cell niche at a glance. J Cell Sci 124: 3529–3535. 10.1242/jcs.074112.22083139
Löfstedt, H; Westberg, H; Seldén, AI; Bryngelsson, IL; Svartengren, M. (2011). Respiratory symptoms and lung function in foundry workers using the hot box method: A 4-year follow-up. J Occup Environ Med 53: 1425–1429. 10.1097/JOM.0b013e3182363c17.22173285
Löfstedt, H; Westberg, H; Seldén, AI; Lundholm, C; Svartengren, M. (2009). Respiratory symptoms and lung function in foundry workers exposed to low molecular weight isocyanates. Am J Ind Med 52: 455–463. 10.1002/ajim.20693.19288497
Lourenço, O; Fonseca, AM; Taborda-Barata, L. (2016). Human CD8+ T Cells in Asthma: Possible Pathways and Roles for NK-Like Subtypes [Review]. 7: 638. 10.3389/fimmu.2016.00638.
Lovreglio, P; Carrus, A; Iavicoli, S; Drago, I; Persechino, B; Soleo, L. (2009). Indoor formaldehyde and acetaldehyde levels in the province of Bari, South Italy, and estimated health risk. J Environ Monit 11: 955–961. 10.1039/b819843h.19436853
Lu, K; Boysen, G; Gao, L; Collins, LB; Swenberg, JA. (2008). Formaldehyde-induced histone modifications in vitro. Chem Res Toxicol 21: 1586–1593. 10.1021/tx8000576.18656964
Lu, K; Collins, LB; Ru, H; Bermudez, E; Swenberg, JA. (2010a). Distribution of DNA adducts caused by inhaled formaldehyde is consistent with induction of nasal carcinoma but not leukemia. Toxicol Sci 116: 441–451. 10.1093/toxsci/kfq061.20176625
Lu, K; Craft, S; Nakamura, J; Moeller, BC; Swenberg, JA. (2012). Use of LC-MS/MS and stable isotopes to differentiate hydroxymethyl and methyl DNA adducts from formaldehyde and nitrosodimethylamine. Chem Res Toxicol 25: 664–675. 10.1021/tx200426b.22148432
Lu, K; Moeller, B; Doyle-Eisele, M; Mcdonald, J; Swenberg, JA. (2011). Molecular dosimetry of N2-hydroxymethyl-dG DNA adducts in rats exposed to formaldehyde. Chem Res Toxicol 24: 159–161. 10.1021/tx1003886.21155545
Lu, K; Ye, W; Zhou, L; Collins, LB; Chen, X; Gold, A; Ball, LM; Swenberg, JA. (2010b). Structural characterization of formaldehyde-induced cross-links between amino acids and deoxynucleosides and their oligomers. J Am Chem Soc 132: 3388–3399. 10.1021/ja908282f.20178313
Lu, Z; Li, CM; Qiao, Y; Liu, Y; Yan, Y; Yang, X. (2005). Type II vanilloid receptor signaling system: One of the possible mechanisms for the rise in asthma cases. Front Biosci 10: 2527–2533. 10.2741/1717.15970515
Luce, D; Gérin, M; Leclerc, A; Morcet, JF; Brugère, J; Goldberg, M. (1993). Sinonasal cancer and occupational exposure to formaldehyde and other substances. Int J Cancer 53: 224–231. 10.1002/ijc.2910530209.8425759
Luce, D; Leclerc, A; Bégin, D; Demers, PA; Gérin, M; Orlowski, E; Kogevinas, M; Belli, S; Bugel, I; Bolm-Audorff, U; Brinton, LA; Comba, P; Hardell, L; Hayes, RB; Magnani, C; Merler, E; Preston-Martin, S; Vaughan, TL; Zheng, W; Boffetta, P. (2002). Sinonasal cancer and occupational exposures: a pooled analysis of 12 case–control studies. Cancer Causes Control 13: 147–157. 10.1023/A:1014350004255.11936821
Luce, D; Leclerc, A; Morcet, JF; Casal-Lareo, A; Gérin, M; Brugère, J; Haguenoer, JM; Goldberg, M. (1992). Occupational risk factors for sinonasal cancer: A case-control study in France. Am J Ind Med 21: 163–175. 10.1002/ajim.4700210206.1536152
Luch, A; Frey, FC; Meier, R; Fei, J; Naegeli, H. (2014). Low-dose formaldehyde delays DNA damage recognition and DNA excision repair in human cells. PLoS ONE 9: e94149. 10.1371/journal.pone.0094149.24722772
Luecken, DJ; Hutzell, WT; Strum, ML; Pouliot, GA. (2012). Regional sources of atmospheric formaldehyde and acetaldehyde, and implications for atmospheric modeling. Atmos Environ 47: 477–490. 10.1016/j.atmosenv.2011.10.005.
Lundberg, JM; Saria, A. (1983). Capsaicin-induced desensitization of airway mucosa to cigarette smoke, mechanical and chemical irritants [Letter]. Nature 302: 251–253. 10.1038/302251a0.6188055
Luo, YL; Guo, HM; Zhang, YL; Chen, PX; Zhu, YX; Huang, JH; Zhou, WL. (2013). Cellular mechanism underlying formaldehyde-stimulated Cl- secretion in rat airway epithelium. PLoS ONE 8: e54494. 10.1371/journal.pone.0054494.23372735
Lyapina, M; Zhelezova, G; Petrova, E; Boev, M. (2004). Flow cytometric determination of neutrophil respiratory burst activity in workers exposed to formaldehyde. Int Arch Occup Environ Health 77: 335–340. 10.1007/s00420-004-0516-3.15127208
Ma, H; Song, X; Zhang, W; Ling, X; Yang, X; Wu, W; Lou, K; Xu, H. (2020). Formaldehyde inhibits development of T lymphocytes in mice. Toxicol Environ Chem 102: 473–489. 10.1080/02772248.2020.1815202.
Ma, L; Weinberg, RA. (2008). MicroRNAs in malignant progression [Review]. Cell Cycle 7: 570–572. 10.4161/cc.7.5.5547.18256538
Madureira, J; Paciência, I; Cavaleiro-Rufo, J; de Oliveira Fernandes, E. (2016). Indoor pollutant exposure among children with and without asthma in Porto, Portugal, during the cold season. Environ Sci Pollut Res Int 23: 20539–20552. 10.1007/s11356-016-7269-x.27464657
Magnani, C; Comba, P; Ferraris, F; Ivaldi, C; Meneghin, M; Terracini, B. (1993). A case-control study of carcinomas of the nose and paranasal sinuses in the woolen textile manufacturing industry. Arch Environ Health 48: 94–97. 10.1080/00039896.1993.9938401.8476310
Main, DM; Hogan, TJ. (1983). Health effects of low level exposure to formaldehyde. J Occup Environ Med 25: 896–900. 10.1097/00043764-198312000-00013.
Malaka, T; Kodama, AM. (1990). Respiratory health of plywood workers occupationally exposed to formaldehyde. Arch Environ Health 45: 288–294. 10.1080/00039896.1990.10118748.2256713
Malek, FA; Möritz, KU; Fanghänel, J. (2003a). Formaldehyde inhalation & open field behaviour in rats. Indian J Med Res 118: 90–96.14680205
Malek, FA; Möritz, KU; Fanghänel, J. (2003b). A study on specific behavioral effects of formaldehyde in the rat. J Exp Anim Sci 42: 160–170. 10.1016/S0939-8600(03)80009-3.
Malek, FA; Möritz, KU; Fanghänel, J. (2003c). A study on the effect of inhalative formaldehyde exposure on water labyrinth test performance in rats. Ann Anat 185: 277–285. 10.1016/S0940-9602(03)80040-7.12801093
Malek, FA; Möritz, KU; Fanghänel, J. (2004). Effects of a single inhalative exposure to formaldehyde on the open field behavior of mice. Int J Hyg Environ Health 207: 151–158. 10.1078/1438-4639-00268.15031957
Malker, HSR; Mclaughlin, JK; Weiner, JA; Silverman, DT; Blot, WJ; JLE, E; Fraumeni, J, r, J. F. (1990). Occupational risk factors for nasopharyngeal cancer in Sweden. Br J Ind Med 47: 213–214. 10.1136/oem.47.3.213.2328228
Mandryk, J; Alwis, KU; Hocking, AD. (2000). Effects of personal exposures on pulmonary function and work-related symptoms among sawmill workers. Ann Occup Hyg 44: 281–289.10831732
Mantovani, A; Allavena, P; Sica, A; Balkwill, F. (2008). Cancer-related inflammation [Review]. Nature 454: 436–444. 10.1038/nature07205.18650914
Marcucci, G; Radmacher, MD; Mrózek, K; Bloomfield, CD. (2009). MicroRNA expression in acute myeloid leukemia [Review]. Curr Hematol Malig Rep 4: 83–88. 10.1007/s11899-009-0012-7.20425419
Marks, GB; Ezz, W; Aust, N; Toelle, BG; Xuan, W; Belousova, E; Cosgrove, C; Jalaludin, B; Smith, WT. (2010). Respiratory health effects of exposure to low-NOx unflued gas heaters in the classroom: A double-blind, cluster-randomized, crossover study. Environ Health Perspect 118: 1476–1482. 10.1289/ehp.1002186.20663737
Maronpot, RR; Miller, RA; Clarke, WJ; Westerberg, RB; Decker, JR; Moss, OR. (1986). Toxicity of formaldehyde vapor in B6C3F1 mice exposed for 13 weeks. Toxicology 41: 253–266. 10.1016/0300-483X(86)90180-0.3775776
Marsh, GM; Stone, RA; Esmen, NA; Henderson, VL. (1994). Mortality patterns among chemical plant workers exposed to formaldehyde and other substances. J Natl Cancer Inst 86: 384–386. 10.1093/jnci/86.5.384.8308930
Marsh, GM; Stone, RA; Esmen, NA; Henderson, VL; Lee, KY. (1996). Mortality among chemical workers in a factory where formaldehyde was used. Occup Environ Med 53: 613–627. 10.1136/oem.53.9.613.8882119
Marsh, GM; Youk, AO. (2005). Reevaluation of mortality risks from nasopharyngeal cancer in the formaldehyde cohort study of the National Cancer Institute. Regul Toxicol Pharmacol 42: 275–283. 10.1016/j.yrtph.2005.05.003.15978711
Marsh, GM; Youk, AO; Buchanich, JM; Cassidy, LD; Lucas, LJ; Esmen, NA; Gathuru, IM. (2002). Pharyngeal cancer mortality among chemical plant workers exposed to formaldehyde. Toxicol Ind Health 18: 257–268. 10.1191/0748233702th149oa.14992463
Marsh, GM; Youk, AO; Buchanich, JM; Erdal, S; Esmen, NA. (2007a). Work in the metal industry and nasopharyngeal cancer mortality among formaldehyde-exposed workers. Regul Toxicol Pharmacol 48: 308–319. 10.1016/j.yrtph.2007.04.006.17544557
Marsh, GM; Youk, AO; Morfeld, P. (2007b). Mis-specified and non-robust mortality risk models for nasopharyngeal cancer in the National Cancer Institute formaldehyde worker cohort study. Regul Toxicol Pharmacol 47: 59–67. 10.1016/j.yrtph.2006.07.007.17000042
Martin, WJ. (1990). A teratology study of inhaled formaldehyde in the rat. Reprod Toxicol 4: 237–239. 10.1016/0890-6238(90)90065-4.2136043
Mashaghi, A; Marmalidou, A; Tehrani, M; Grace, PM; Pothoulakis, C; Dana, R. (2016). Neuropeptide substance P and the immune response [Review]. Cell Mol Life Sci 73: 4249–4264. 10.1007/s00018-016-2293-z.27314883
Massberg, S; Schaerli, P; Knezevic-Maramica, I; Köllnberger, M; Tubo, N; Moseman, EA; Huff, IV; Junt, T; Wagers, AJ; Mazo, IB; von Andrian, UH. (2007). Immunosurveillance by hematopoietic progenitor cells trafficking through blood, lymph, and peripheral tissues. Cell 131: 994–1008. 10.1016/j.cell.2007.09.047.18045540
Matanoski, GM. (1989). Risks of pathologists exposed to formaldehyde (final report). (DHHS Grant No. 5 R01-OH-01511-03). Baltimore, MD: Johns Hopkins University Department of Epidemiology. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB91173682.
Matsunaga, I; Miyake, Y; Yoshida, T; Miyamoto, S; Ohya, Y; Sasaki, S; Tanaka, K; Oda, H; Ishiko, O; Hirota, Y; Group, OMaCHS. (2008). Ambient formaldehyde levels and allergic disorders among Japanese pregnant women: Baseline data from the Osaka maternal and child health study. Ann Epidemiol 18: 78–84. 10.1016/j.annepidem.2007.07.095.18063241
Matsunaga, M. (2012). [Email to Glinda Cooper regarding follow-up on formaldehyde-allergy-asthma study].
Matsuoka, T; Takaki, A; Ohtaki, H; Shioda, S. (2010). Early changes to oxidative stress levels following exposure to formaldehyde in ICR mice. J Toxicol Sci 35: 721–730. 10.2131/jts.35.721.20930466
Mayr, SI; Hafizovic, K; Waldfahrer, F; Iro, H; Kütting, B. (2010). Characterization of initial clinical symptoms and risk factors for sinonasal adenocarcinomas: results of a case-control study. Int Arch Occup Environ Health 83: 631–638. 10.1007/s00420-009-0479-5.19885670
Mazzone, SB; Undem, BJ. (2016). Vagal afferent innervation of the airways in health and disease [Review]. Physiol Rev 96: 975–1024. 10.1152/physrev.00039.2015.27279650
McConnell, EE; Solleveld, HA; Swenberg, JA; Boorman, GA. (1986). Guidelines for combining neoplasms for evaluation of rodent carcinogenesis studies. J Natl Cancer Inst 76: 283–289. 10.1093/jnci/76.2.283.3456066
Mcgrady, AV. (1984). Effects of psychological stress on male reproduction - A review. Arch Androl 13: 1–7. 10.3109/01485018408987495.6152527
Mcgregor, D; Bolt, H; Cogliano, V; Richter-Reichhelm, HB. (2006). Formaldehyde and glutaraldehyde and nasal cytotoxicity: Case study within the context of the 2006 IPCS Human Framework for the Analysis of a cancer mode of action for humans [Review]. Crit Rev Toxicol 36: 821–835. 10.1080/10408440600977669.17118731
Mchale, CM; Smith, MT; Zhang, L. (2014). Application of toxicogenomic profiling to evaluate effects of benzene and formaldehyde: from yeast to human [Review]. Ann N Y Acad Sci 1310: 74–83. 10.1111/nyas.12382.24571325
Mchale, CM; Zhang, L; Smith, MT. (2012). Current understanding of the mechanism of benzene-induced leukemia in humans: implications for risk assessment [Review]. Carcinogenesis 33: 240–252. 10.1093/carcin/bgr297.22166497
Mcnamara, CR; Mandel-Brehm, J; Bautista, DM; Siemens, J, an; Deranian, KL; Zhao, M; Hayward, NJ; Chong, JA; Julius, D; Moran, MM; Fanger, CM. (2007). TRPA1 mediates formalin-induced pain. Proc Natl Acad Sci USA 104: 13525–13530. 10.1073/pnas.0705924104.17686976
Meek, ME; Boobis, A; Cote, I; Dellarco, V; Fotakis, G; Munn, S; Seed, J; Vickers, C. (2014). New developments in the evolution and application of the WHO/IPCS framework on mode of action/species concordance analysis [Review]. J Appl Toxicol 34: 1–18. 10.1002/jat.2949.24166207
Mei, YF; Duan, CL; Li, XX; Zhao, Y; Cao, FH; Shang, S; Ding, SM; Yue, XP; Gao, G; Yang, H; Shen, LX; Feng, XY; Jia, JP; Tong, ZQ; Yang, X. (2016). Reduction of Endogenous Melatonin Accelerates Cognitive Decline in Mice in a Simulated Occupational Formaldehyde Exposure Environment. Int J Environ Res Public Health 13. 10.3390/ijerph13030258.
Mendell, MJ; Mirer, AG; Cheung, K; Tong, M; Douwes, J. (2011). Respiratory and allergic health effects of dampness, mold, and dampness-related agents: a review of the epidemiologic evidence [Review]. Environ Health Perspect 119: 748–756. 10.1289/ehp.1002410.21269928
Menezes, AM; Pérez-Padilla, R; Wehrmeister, FC; Lopez-Varela, MV; Muiño, A; Valdivia, G; Lisboa, C; Jardim, J. R.; de Oca, MM; Talamo, C; Bielemann, R; Gazzotti, M; Laurenti, R; Celli, B; Victora, CG; team, P. (2014). FEV1 is a better predictor of mortality than FVC: the PLATINO cohort study. PLoS ONE 9: e109732. 10.1371/journal.pone.0109732.25285441
Meng, F; Bermudez, E; Mckinzie, PB; Andersen, ME; III, C H; Parsons, BL. (2010). Measurement of tumor-associated mutations in the nasal mucosa of rats exposed to varying doses of formaldehyde. Regul Toxicol Pharmacol 57: 274–283. 10.1016/j.yrtph.2010.03.007.20347909
Mercer, RR; Russell, ML; Roggli, VL; Crapo, JD. (1994). Cell number and distribution in human and rat airways. Am J Respir Cell Mol Biol 10: 613–624. 10.1165/ajrcmb.10.6.8003339.8003339
Merler, E; Baldasseroni, A; laria, R; Faravelli, P; Agostini, R; Pisa, R; Berrino, F. (1986). On the causal association between exposure to leather dust and nasal cancer: Further evidence from a case-control study. Br J Ind Med 43: 91–95. 10.1136/oem.43.2.91.3947574
Mery, S; Gross, EA; Joyner, DR; Godo, M; Morgan, KT. (1994). Nasal diagrams: A tool for recording the distribution of nasal lesions in rats and mice. Toxicol Pathol 22: 353–372. 10.1177/019262339402200402.7817125
Meyers, AR; Pinkerton, LE; Hein, MJ. (2013). Cohort mortality study of garment industry workers exposed to formaldehyde: Update and internal comparisons. Am J Ind Med 56: 1027–1039. 10.1002/ajim.22199.23788124
Mi, S; Lu, J; Sun, M; Li, Z; Zhang, H; Neilly, MB; Wang, Y; Qian, Z; Jin, J; Zhang, Y; Bohlander, SK; Le Beau, MM; Larson, RA; Golub, TR; Rowley, JD; Chen, J. (2007). MicroRNA expression signatures accurately discriminate acute lymphoblastic leukemia from acute myeloid leukemia. Proc Natl Acad Sci USA 104: 19971–19976. 10.1073/pnas.0709313104.18056805
Mi, YH; Norbäck, D; Tao, J; Mi, YL; Ferm, M. (2006). Current asthma and respiratory symptoms among pupils in Shanghai, China: Influence of building ventilation, nitrogen dioxide, ozone, and formaldehyde in classrooms. Indoor Air 16: 454–464. 10.1111/j.1600-0668.2006.00439.x.17100666
Mikhed, Y; Goerlach, A; Knaus, UG; Daiber, A. (2015). Redox regulation of genome stability by effects on gene expression, epigenetic pathways and DNA damage/repair [Review]. 5: 275–289. 10.1016/j.redox.2015.05.008.
Miller, FJ; Conolly, RB; Kimbell, JS. (2017). An updated analysis of respiratory tract cells at risk for formaldehyde carcinogenesis. Inhal Toxicol 29: 586–597. 10.1080/08958378.2018.1430191.29405084
Miller, MR; Crapo, R; Hankinson, J; Brusasco, V; Burgos, F; Casaburi, R; Coates, A; Enright, P; van Der Grinten, CP; Gustafsson, P; Jensen, R; Johnson, DC; Macintyre, N; Mckay, R; Navajas, D; Pedersen, OF; Pellegrino, R; Viegi, G; Wanger, J; Force, AET. (2005a). General considerations for lung function testing [Review]. Eur Respir J 26: 153–161. 10.1183/09031936.05.00034505.15994402
Miller, MR; Hankinson, J; Brusasco, V; Burgos, F; Casaburi, R; Coates, A; Crapo, R; Enright, P; van Der Grinten, CP; Gustafsson, P; Jensen, R; Johnson, DC; Macintyre, N; Mckay, R; Navajas, D; Pedersen, OF; Pellegrino, R; Viegi, G; Wanger, J; Force, AET. (2005b). Standardisation of spirometry. Eur Respir J 26: 319–338. 10.1183/09031936.05.00034805.16055882
Milton, DK; Wypij, D; Kriebel, D; Walters, MD; Hammond, SK; Evans, JS. (1996). Endotoxin exposure-response in a fiberglass manufacturing facility. Am J Ind Med 29: 3–13. 10.1002/(SICI)1097-0274(199601)29:1<3::AID-AJIM2>3.0.CO;2-V.8808037
Moeller, BC; Lu, K; Doyle-Eisele, M; Mcdonald, J; Gigliotti, A; Swenberg, JA. (2011). Determination of N2-hydroxymethyl-dG adducts in the nasal epithelium and bone marrow of nonhuman primates following 13CD2-formaldehyde inhalation exposure. Chem Res Toxicol 24: 162–164. 10.1021/tx1004166.21222454
Mohammad `pour, AA; Maleki, M. (2011). Effect of formaldehyde exposure on pulmonary function tests of veterinary students in anatomy laboratory. Journal of Applied Animal Research 39: 114–116. 10.1080/09712119.2011.558678.
Möhner, M; Liu, Y; Marsh, GM. (2019). New insights into the mortality risk from nasopharyngeal cancer in the national cancer institute formaldehyde worker cohort study. J Occup Med Toxicol 14: 4. 10.1186/s12995-019-0224-2.30828355
Møller, P; Scholten, RH; Roursgaard, M; Krais, AM. (2020). Inflammation, oxidative stress and genotoxicity responses to biodiesel emissions in cultured mammalian cells and animals [Review]. Crit Rev Toxicol 50: 383–401. 10.1080/10408444.2020.1762541.32543270
Monfared, AL. (2012). Histomorphological and ultrastructural changes of the placenta in mice exposed to formaldehyde. Toxicol Ind Health 30: 174–181. 10.1177/0748233712452603.22778113
Monteiro-Riviere, NA; Popp, JA. (1986). Ultrastructural evaluation of acute nasal toxicity in the rat respiratory epithelium in response to formaldehyde gas. Fundam Appl Toxicol 6: 251–262. 10.1016/0272-0590(86)90238-1.3699315
Monticello, TM; Gross, EA; Morgan, KT. (1993). Cell Proliferation and Nasal Carcinogenesis. Environ Health Perspect 101: 121. 10.2307/3431854.
Monticello, TM; Miller, FJ; Morgan, KT. (1991). Regional increases in rat nasal epithelial cell proliferation following acute and subchronic inhalation of formaldehyde. Toxicol Appl Pharmacol 111: 409–421. 10.1016/0041-008X(91)90246-B.1746023
Monticello, TM; Morgan, KT. (1994). Cell proliferation and formaldehyde-induced respiratory carcinogenesis [Review]. Risk Anal 14: 313–319. 10.1111/j.1539-6924.1994.tb00246.x.8029503
Monticello, TM; Morgan, KT; Everitt, JI; Popp, JA. (1989). Effects of formaldehyde gas on the respiratory tract of rhesus monkeys: Pathology and cell proliferation. Am J Pathol 134: 515–527.2923182
Monticello, TM; Morgan, KT; Hurtt, ME. (1990a). Unit length as the denominator for quantitation of cell proliferation in nasal epithelia. Toxicol Pathol 18: 24–31. 10.1177/019262339001800104.2194274
Monticello, TM; Morgan, KT; Uraih, L. (1990b). Nonneoplastic nasal lesions in rats and mice [Review]. Environ Health Perspect 85: 249–274.2200665
Monticello, TM; Swenberg, JA; Gross, EA; Leininger, JR; Kimbell, JS; Seilkop, S; Starr, TB; Gibson, JE; Morgan, KT. (1996). Correlation of regional and nonlinear formaldehyde-induced nasal cancer with proliferating populations of cells. Cancer Res 56: 1012–1022.8640755
Moolgavkar, SH; Dewanji, A; Venzon, DJ. (1988). A stochastic two-stage model for cancer risk assessment. I. The hazard function and the probability of tumor. Risk Anal 8: 383–392. 10.1111/j.1539-6924.1988.tb00502.x.3201016
Moolgavkar, SH; Knudson, AG, Jr. (1981). Mutation and cancer: a model for human carcinogens. J Natl Cancer Inst 66: 1037–1052.6941039
Moolgavkar, SH; Luebeck, EG. (1992). Interpretation of labeling indices in the presence of cell death. Carcinogenesis 13: 1007–1010. 10.1093/carcin/13.6.1007.1600603
Moolgavkar, SH; Venzon, DJ. (1979). Two-event models for carcinogenesis: Incidence curves for childhood and adult tumors. Math Biosci 47: 55–77. 10.1016/0025-5564(79)90005-1.
Moore, KW; de Waal Malefyt, R; Coffman, RL; O’Garra, A. (2001). Interleukin-10 and the interleukin10 receptor [Review]. Annu Rev Immunol 19: 683–765. 10.1146/annurev.immunol.19.1.683.11244051
Morgan, DL; Dixon, D; King, DH; Travlos, GS; Herbert, RA; French, JE; Tokar, EJ; Waalkes, MP; Jokinen, MP. (2017). NTP research report on absence of formaldehyde-induced neoplasia in Trp53 haploinsufficient mice exposed by inhalation. (Research Report 3). Research Triangle Park, NC: National Toxicology Program. 10.22427/NTP-RR-3.
Morgan, KT. (1997). A brief review of formaldehyde carcinogenesis in relation to rat nasal pathology and human health risk assessment [Review]. Toxicol Pathol 25: 291–305. 10.1177/019262339702500307.9210261
Morgan, KT; Gross, EA; Patterson, DL. (1986a). Distribution, progression, and recovery of acute formaldehyde-induced inhibition of nasal mucociliary function in F-344 rats. Toxicol Appl Pharmacol 86: 448–456. 10.1016/0041-008X(86)90372-8.3787637
Morgan, KT; Jiang, XZ; Starr, TB; Kerns, WD. (1986b). More precise localization of nasal tumors associated with chronic exposure of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82: 264–271. 10.1016/0041-008X(86)90201-2.3945953
Morgan, KT; Kimbell, JS; Monticello, TM; Patra, AL; Fleishman, A. (1991). Studies of inspiratory airflow patterns in the nasal passages of the F344 rat and rhesus monkey using nasal molds: Relevance to formaldehyde toxicity. Toxicol Appl Pharmacol 110: 223–240. 10.1016/S0041-008X(05)80005-5.1891770
Morgan, KT; Patterson, DL; Gross, EA. (1984). Frog palate mucociliary apparatus: Structure, function, and response to formaldehyde gas. Fundam Appl Toxicol 4: 58–68. 10.1016/0272-0590(84)90219-7.6607184
Morgan, KT; Patterson, DL; Gross, EA. (1986c). Responses of the nasal mucociliary apparatus of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82: 1–13. 10.1016/0041-008X(86)90431-X.3945936
Morgan, KT; Patterson, DL; Gross, EA. (1983). Formaldehyde and the nasal mucociliary apparatus. In JJ Clary; JE Gibson; RS Waritz (Eds.), Formaldehyde: toxicology, epidemiology, mechanisms (pp. 193–209). New York, NY: Marcel Dekker, Inc.
Mori, M; Matsumoto, Y; Kushino, N; Morimatsu, Y; Hoshiko, M; Saga, T; Yamaki, K; Ishitake, T. (2016). Comparison of subjective symptoms associated with exposure to low levels of formaldehyde between students enrolled and not enrolled in a gross anatomy course. Environ Health Prev Med 21: 34–41. 10.1007/s12199-015-0497-8.26498185
Morren, MA; Przybilla, B; Bamelis, M; Heykants, B; Reynaers, A; Degreef, H. (1994). Atopic dermatitis: Triggering factors [Review]. J Am Acad Dermatol 31: 467–473. 10.1016/S0190-9622(94)70213-6.8077475
Morrow, JD; Frei, B; Longmire, AW; Gaziano, JM; Lynch, SM; Shyr, Y; Strauss, WE; Oates, JA; Roberts, LJ. (1995). Increase in circulating products of lipid peroxidation (F2-isoprostanes) in smokers. Smoking as a cause of oxidative damage. N Engl J Med 332: 1198–1203. 10.1056/NEJM199505043321804.7700313
Morton, LM; Gibson, TM; Clarke, CA; Lynch, CF; Anderson, LA; Pfeiffer, R; Landgren, O; Weisenburger, DD; Engels, EA. (2014). Risk of myeloid neoplasms after solid organ transplantation. Leukemia 28: 2317–2323. 10.1038/leu.2014.132.24727673
Mueller, JU; Bruckner, T; Triebig, G. (2013). Exposure study to examine chemosensory effects of formaldehyde on hyposensitive and hypersensitive males. Int Arch Occup Environ Health 86: 107–117. 10.1007/s00420-012-0745-9.22371090
Mullane, K; Williams, M. (2014). Animal models of asthma: Reprise or reboot? [Review]. Biochem Pharmacol 87: 131–139. 10.1016/j.bcp.2013.06.026.23831953
Mullen, NA; Li, J; Russell, ML; Spears, M; Less, BD; Singer, BC. (2015). Results of the California healthy homes indoor air quality study of 2011-2013: Impact of natural gas appliances on air pollutant concentrations. Indoor Air 26: 231–245. 10.1111/ina.12190.25647016
Mundt, KA; Gallagher, AE; Dell, LD; Natelson, EA; Boffetta, P; Gentry, PR. (2017). Does occupational exposure to formaldehyde cause hematotoxicity and leukemia-specific chromosome changes in cultured myeloid progenitor cells? [Review]. Crit Rev Toxicol 47: 1–11. 10.1080/10408444.2017.1301878.27537422
Murphy, MW; Lando, JF; Kieszak, SM; Sutter, ME; Noonan, GP; Brunkard, JM; McGeehin, MA. (2013). Formaldehyde levels in FEMA-supplied travel trailers, park models, and mobile homes in Louisiana and Mississippi. Indoor Air 23: 134–141. 10.1111/j.1600-0668.2012.00800.x.22804791
Murrell, W; Féron, F; Wetzig, A; Cameron, N; Splatt, K; Bellette, B; Bianco, J; Perry, C; Lee, G; Mackay-Sim, A. (2005). Multipotent stem cells from adult olfactory mucosa. Dev Dyn 233: 496–515. 10.1002/dvdy.20360.15782416
Murta, GL; Duarte Campos, KK; Balthar Bandeira, A; Diniz, MF; Costa, G; Costa, DC; Talvani, A; Lima, WG; Bezerra, FS. (2016). Oxidative effects on lung inflammatory response in rats exposed to different concentrations of formaldehyde. Environ Pollut 211: 206–213. 10.1016/j.envpol.2015.12.054.26774767
Musak, L; Smerhovsky, Z; Halasova, E; Osina, O; Letkova, L; Vodickova, L; Polakova, V; Buchancova, J; Hemminki, K; Vodicka, P. (2013). Chromosomal damage among medical staff occupationally exposed to volatile anesthetics, antineoplastic drugs, and formaldehyde. Scand J Work Environ Health 39: 618–630. 10.5271/sjweh.3358.23525098
Nakamura, J; Holley, DW; Kawamoto, T; Bultman, SJ. (2020). The failure of two major formaldehyde catabolism enzymes (ADH5 and ALDH2) leads to partial synthetic lethality in C57BL/6 mice. Genes Environ 42: 21. 10.1186/s41021-020-00160-4.32514323
Nakano, T; Katafuchi, A; Matsubara, M; Terato, H; Tsuboi, T; Masuda, T; Tatsumoto, T; Pack, SP; Makino, K; Croteau, DL; Van Houten, B; Iijima, K; Tauchi, H; Ide, H. (2009). Homologous recombination but not nucleotide excision repair plays a pivotal role in tolerance of DNA-protein cross-links in mammalian cells. J Biol Chem 284: 27065–27076. 10.1074/jbc.M109.019174.19674975
Nalivaiko, E; De Pasquale, CG; Blessing, WW. (2003). Electrocardiographic changes associated with the nasopharyngeal reflex in conscious rabbits: Vago-sympathetic co-activation. Auton Neurosci 105: 101–104. 10.1016/s1566-0702(03)00048-1.12798206
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA’s ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2023). Review of EPA’s 2022 Draft Formaldehyde Assessment. Washington, DC. https://nap.nationalacademies.org/catalog/27153/review-of-epas-2022-draft-formaldehyde-assessment.
Navarro-Costa, P; Nogueira, P; Carvalho, M; Leal, F; Cordeiro, I; Calhaz-Jorge, C; Gonçalves, J; Plancha, CE. (2010). Incorrect DNA methylation of the DAZL promoter CpG island associates with defective human sperm. Hum Reprod 25: 2647–2654. 10.1093/humrep/deq200.20685756
NCI (National Cancer Institute). (2012). Mortality - All cause of death, total U.S. (1969-2010), from the surveillance, epidemiology, and end results program. Available online at http://seer.cancer.gov/mortality/.
Neamtiu, IA; Lin, S; Chen, ML; Roba, C; Csobod, E, va; Gurzau, ES. (2019). Assessment of formaldehyde levels in relation to respiratory and allergic symptoms in children from Alba County schools, Romania. Environ Monit Assess 191: 591. 10.1007/s10661-019-7768-6.31446497
Neghab, M; Soltanzadeh, A; Choobineh, A. (2011). Respiratory morbidity induced by occupational inhalation exposure to formaldehyde. Ind Health 49: 89–94. 10.2486/indhealth.MS1197.20823630
Negro-Vilar, A. (1993). Stress and other environmental factors affecting fertility in men and women: Overview. Environ Health Perspect 101 Suppl. 2: 59. 10.2307/3431377.
Neuss, S; Moepps, B; Speit, G. (2010). Exposure of human nasal epithelial cells to formaldehyde does not lead to DNA damage in lymphocytes after co-cultivation. Mutagenesis 25: 359–364. 10.1093/mutage/geq013.20299426
Nielsen, GD. (1991). Mechanisms of activation of the sensory irritant receptor by airborne chemicals [Review]. Crit Rev Toxicol 21: 183–208. 10.3109/10408449109089879.2039594
Nielsen, GD; Hougaard, KS; Larsen, ST; Hammer, M; Wolkoff, P; Clausen, PA; Wilkins, CK; Alarie, Y. (1999). Acute airway effects of formaldehyde and ozone in BALB/c mice. Hum Exp Toxicol 18: 400–409. 10.1191/096032799678840246.10413245
Nilsson, JA; Hedberg, JJ; Vondracek, M; Staab, CA; Hansson, A; Hoog, JO; Grafstrom, RC. (2004). Alcohol dehydrogenase 3 transcription associates with proliferation of human oral keratinocytes. Cell Mol Life Sci 61: 610–617. 10.1007/s00018-003-3433-9.15004699
Nilsson, JA; Zheng, X; Sundqvist, K; Liu, Y; Atzori, L; Elfwing, A; Arvidson, K; Grafström, RC. (1998). Toxicity of formaldehyde to human oral fibroblasts and epithelial cells: influences of culture conditions and role of thiol status. J Dent Res 77: 1896–1903. 10.1177/00220345980770110601.9823728
NIOSH (National Institute for Occupational Safety and Health). (1994). Formaldehyde method 3500. In NIOSH manual of analytical methods (4th ed., pp. 3500-3501 – 3500-3504). (DHHS/NIOSH Pub. 84-100). Washington, DC. https://www.cdc.gov/niosh/docs/2003-154/pdfs/3500.pdf.
Noda, T; Takahashi, A; Kondo, N; Mori, E; Okamoto, N; Nakagawa, Y; Ohnishi, K; Zdzienicka, MZ; Thompson, LH; Helleday, T; Asada, H; Ohnishi, T. (2011). Repair pathways independent of the Fanconi anemia nuclear core complex play a predominant role in mitigating formaldehyde-induced DNA damage. Biochem Biophys Res Commun 404: 206–210. 10.1016/j.bbrc.2010.11.094.21111709
Norback, D; Bjornsson, E; Janson, C; Widstrom, J; Boman, G. (1995). Asthmatic symptoms and volatile organic compounds, formaldehyde, and carbon dioxide in dwellings. Occup Environ Med 52: 388–395. 10.1136/oem.52.6.388.7627316
Norbäck, D; Hashim, JH; Hashim, Z; Ali, F. (2017). Volatile organic compounds (VOC), formaldehyde and nitrogen dioxide (NO2) in schools in Johor Bahru, Malaysia: Associations with rhinitis, ocular, throat and dermal symptoms, headache and fatigue. Sci Total Environ 592: 153–160. 10.1016/j.scitotenv.2017.02.215.28319702
Norback, D; Walinder, R; Wieslander, G; Smedje, G; Erwall, C; Venge, P. (2000). Indoor air pollutants in schools: nasal patency and biomarkers in nasal lavage. Allergy 55: 163–170. 10.1034/j.1398-9995.2000.00353.x.10726731
Nordman, H; Keskinen, H; Tuppurainen, M. (1985). Formaldehyde asthma--rare or overlooked? J Allergy Clin Immunol 75: 91–99. 10.1016/0091-6749(85)90018-1.3968333
Norsted, SW; Kozinetz, CA; Annegers, JF. (1985). Formaldehyde complaint investigations in mobile homes by the Texas Department of Health. Environ Res 37: 93–100. 10.1016/0013-9351(85)90052-0.3996345
NRC (National Research Council). (2001). Standing operating procedures for developing acute exposure guideline levels (AEGLs) for hazardous chemicals. Washington, DC: National Academies Press. 10.17226/10122.
NRC (National Research Council). (2011). Review of the Environmental Protection Agency’s draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142.
NRC (National Research Council). (2014a). Review of EPA’s Integrated Risk Information System (IRIS) process. Washington, DC: The National Academies Press. 10.17226/18764.
NRC (National Research Council). (2014b). Review of the Formaldehyde Assessment in the National Toxicology Program 12th Report on Carcinogens. Washington (DC): National Academies Press (US). 10.17226/18948.
NTP (National Toxicology Program). (1988). Toxicology and carcinogenesis studies of 1,2-epoxybutane (CAS no. 106-88-7) in F344/N rats and B6C3F1 mice (inhalation studies) [NTP]. (PB88216262. NTP TR 329).
NTP (National Toxicology Program). (2010). Final report on carcinogens. Background document for formaldehyde [NTP] (pp. i–512).
NTP (National Toxicology Program). (2011). Report on carcinogens. Twelfth Edition, 2011 (12th ed., pp. 507). (NTP TR 581 126). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2011111646.xhtml.
NTP (National Toxicology Program). (2014). 13th Report on carcinogens [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service.
NTP (National Toxicology Program). (2015). Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. Research Triangle Park, NC: U.S. Deptartment of Health and Human Services, National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf.
Nunn, AJ; Craigen, AA; Darbyshire, JH; Venables, KM; Taylor, AJN. (1990). Six year follow up of lung function in men occupationally exposed to formaldehyde. Br J Ind Med 47: 747–752. 10.1136/oem.47.11.747.2245186
O’Connor, TM; O’Halloran, DJ; Shanahan, F. (2000). The stress response and the hypothalamic-pituitary-adrenal axis: from molecule to melancholia [Review]. QJM 93: 323–333.10873181
Oberbeck, N; Langevin, F; King, G; de Wind, N; Crossan, GP; Patel, KJ. (2014). Maternal aldehyde elimination during pregnancy preserves the fetal genome. Mol Cell 55: 807–817. 10.1016/j.molcel.2014.07.010.25155611
Odkvist, LM; Edling, C; Hellquist, H. (1985). Influence of vapours on the nasal mucosa among industry workers. Rhinology 23: 121–127.4035241
OECD (Organisation for Economic Co-operation and Development). (2009). Series on testing and assesment: Number 39. Guidance document on acute inhalation toxicity testing [OECD SIDS]. (ENV/JM/MONO(2009)28; JT03268144). Paris, Fr. http://search.oecd.org/officialdocuments/displaydocumentpdf/?cote=env/jm/mono%282009%2928&doclanguage=en.
OECD (Organisation for Economic Co-operation and Development). (2013). Guidance document supporting OECD test guideline 443 on the extended one generation reproductive toxicity test. (No. 151 / ENV/JM/MONO(2013)10). Paris, France: OECD Environment, Health and Safety Publications. http://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=ENV/JM/MONO%282013%2910&doclanguage=en.
OEHHA (California Office of Environmental Health Hazard Assessment). (2003). Air pollution and children’s health [Fact Sheet]. http://oehha.ca.gov/public_info/facts/airkids.html.
OEHHA (California Office of Environmental Health Hazard Assessment). (2008). Draft Technical Support Document for Noncancer Risk Assessment. Appendix G. Value of the Haber’s Law Exponent (n) for various gases and vapors for acute RELs developed using OEHHA (1999) procedures.
Ohmichi, K; Komiyama, M; Matsuno, Y; Sawabe, Y; Miyaso, H; Fukata, H; Ohmichi, M; Kadota, T; Nomura, F; Moria, C. (2006). Relationship between exposure to formaldehyde and immunoglobulin E (IgE) production during the gross anatomy laboratory. J Health Sci 52: 642–647. 10.1248/jhs.52.642.
Ohtsuka, R; Shuto, Y; Fujie, H; Takeda, M; Harada, T; Itagaki, S. (1997). Response of respiratory epithelium of BN and F344 rats to formaldehyde inhalation. Exp Anim 46: 279–286. 10.1538/expanim.46.279.9353635
Ojajärvi, IA; Partanen, TJ; Ahlbom, A; Boffetta, P; Hakulinen, T; Jourenkova, N; Kauppinen, TP; Kogevinas, M; Porta, M; Vainio, HU; Weiderpass, E; Wesseling, CH. (2000). Occupational exposures and pancreatic cancer: A meta-analysis. Occup Environ Med 57: 316–324. 10.1136/oem.57.5.316.10769297
Olsen, J; Jensen, O. (1984). Case-control study on sinonasal cancer and formaldehyde exposure based on a national data linkage system for occupation and cancer [Abstract]. Am J Epidemiol 120: 459.
Olsen, JH; Asnaes, S. (1986). Formaldehyde and the risk of squamous cell carcinoma of the sinonasal cavities. Br J Ind Med 43: 769–744. 10.1136/oem.43.11.769.3790457
Olsen, JH; Dossing, M. (1982). Formaldehyde induced symptoms in day care centers. AIHA J 43: 366–370. 10.1080/15298668291409866.
Olsen, JH; Jensen, SP; Hink, M; Faurbo, K; Breum, NO; Jensen, ON. (1984). Occupational formaldehyde exposure and increased nasal cancer risk in man. Int J Cancer 34: 639–644. 10.1002/ijc.2910340509.6500742
Ostojić, L; Bradarić, A; Mise, K; Ostojić, Z; Lovrić, J; Petrović, P; Ujević, A; Erceg, M; Janković, S; Tocilj, J. (2006). Pulmonary function in persons who are professionally exposed to formaldehyde fumes. Coll Antropol 30: 507–511.17058515
Ott, MG; Teta, J; Greenberg, HL. (1989). Lymphatic and hematopoietic tissue cancer in a chemical manufacturing environment. Am J Ind Med 16: 631–644. 10.1002/ajim.4700160603.2556914
Overton, JH; Kimbell, JS; Miller, FJ. (2001). Dosimetry modeling of inhaled formaldehyde: The human respiratory tract. Toxicol Sci 64: 122–134. 10.1093/toxsci/64.1.122.11606808
Ozen, OA; Akpolat, N; Songur, A; Kuş, I; Zararsiz, I; Ozaçmak, VH; Sarsilmaz, M. (2005). Effect of formaldehyde inhalation on Hsp70 in seminiferous tubules of rat testes: An immunohistochemical study. Toxicol Ind Health 21: 249–254. 10.1191/0748233705th235oa.16463957
Ozen, OA; Songue, A; Sars, M; Yaman, M; Kus, I. (2003). Changes of zinc, copper, and iron levels in the lung of male rats after subacute (4-week) and subchronic (13-week) exposure to formaldehyde. J Trace Elem Exp Med 16: 67–74. 10.1002/jtra.10026.
Ozen, OA; Yaman, M; Sarsilmaz, M; Songur, A; Kus, I. (2002). Testicular zinc, copper and iron concentrations in male rats exposed to subacute and subchronic formaldehyde gas inhalation. J Trace Elem Med Biol 16: 119–122. 10.1016/S0946-672X(02)80038-4.12195726
Paiva, RM; Calado, RT. (2014). Telomere dysfunction and hematologic disorders [Review]. 125: 133–157. 10.1016/B978-0-12-397898-1.00006-2.
Palczynski, C; Krakowiak, A; Hanke, W; Walusiak, J; Gorski, P. (1999). Indoor formaldehyde exposure and airway allergic diseases. Int Rev Allergol Clin Immunol 5: 65–69.
Palma, T. (2018). RE: NATA 2011 data.
Park, J; Yang, H; Song, MK; Kim, D; Lee, K. (2020). Formaldehyde exposure induces regulatory T cell-mediated immunosuppression via calcineurin-NFAT signalling pathway. Sci Rep 10: 17023. 10.1038/s41598-020-72502-9.33046725
Paydas, S; Zorludemir, S; Ergin, M. (2006). Granulocytic sarcoma: 32 cases and review of the literature. Leuk Lymphoma 47: 2527–2541. 10.1080/10428190600967196.17169797
Pazdrak, K; Gorski, P; Krakowiak, A; Ruta, U. (1993). Changes in nasal lavage fluid due to formaldehyde inhalation. Int Arch Occup Environ Health 64: 515–519. 10.1007/BF00381101.8482593
Pedersen-Bjergaard, J; Christiansen, DH; Desta, F; Andersen, MK. (2006). Alternative genetic pathways and cooperating genetic abnormalities in the pathogenesis of therapy-related myelodysplasia and acute myeloid leukemia [Review]. Leukemia 20: 1943–1949. 10.1038/sj.leu.2404381.16990778
Pellegrino, R; Viegi, G; Brusasco, V; Crapo, RO; Burgos, F; Casaburi, R; Coates, A; van Der Grinten, CP; Gustafsson, P; Hankinson, J; Jensen, R; Johnson, DC; Macintyre, N; Mckay, R; Miller, MR; Navajas, D; Pedersen, OF; Wanger, J. (2005). Interpretative strategies for lung function tests. Eur Respir J 26: 948–968. 10.1183/09031936.05.00035205.16264058
Percy, C; Stanek, E, III; Gloeckler, L. (1981). Accuracy of cancer death certificates and its effect on cancer mortality statistics. Am J Public Health 71: 242–250. 10.2105/AJPH.71.3.242.7468855
Percy, CL; Miller, BA; Gloeckler Ries, LA. (1990). Effect of changes in cancer classification and the accuracy of cancer death certificates on trends in cancer mortality. Ann N Y Acad Sci 609: 87–99. 10.1111/j.1749-6632.1990.tb32059.x.2264660
Pesch, B; Pierl, CB; Gebel, M; Gross, I; Becker, D; Johnen, G; Rihs, HP; Donhuijsen, K; Lepentsiotis, V; Meier, M; Schulze, J; Brüning, T. (2008). Occupational risks for adenocarcinoma of the nasal cavity and paranasal sinuses in the German wood industry. Occup Environ Med 65: 191–196. 10.1136/oem.2007.033886.17881467
Peteffi, GP; Basso da Silva, L; Antunes, MV; Wilhelm, C; Valandro, ET; Glaeser, J; Kaefer, D; Linden, R. (2015). Evaluation of genotoxicity in workers exposed to low levels of formaldehyde in a furniture manufacturing facility. Toxicol Ind Health 32: 1763–1773. 10.1177/0748233715584250.25971585
Peters, TL; Kamel, F; Lundholm, C; Feychting, M; Weibull, CE; Sandler, DP; Wiebert, P; Sparén, P; Ye, W; Fang, F. (2017). Occupational exposures and the risk of amyotrophic lateral sclerosis. Occup Environ Med 74: 87–92. 10.1136/oemed-2016-103700.27418175
Pinkerton, LE; Hein, MJ; Meyers, A; Kamel, F. (2013). Assessment of ALS mortality in a cohort of formaldehyde-exposed garment workers. 14: 353–355. 10.3109/21678421.2013.778284.
Pinkerton, LE; Hein, MJ; Stayner, LT. (2004). Mortality among a cohort of garment workers exposed to formaldehyde: an update. Occup Environ Med 61: 193–200. 10.1136/oem.2003.007476.14985513
Pira, E; Romano, C; Verga, F; La Vecchia, C. (2014). Mortality from lymphohematopoietic neoplasms and other causes in a cohort of laminated plastic workers exposed to formaldehyde. Cancer Causes Control 25: 1343–1349. 10.1007/s10552-014-0440-0.25053406
Pitten, FA; Kramer, A; Herrmann, K; Bremer, J; Koch, S. (2000). Formaldehyde neurotoxicity in animal experiments. Pathol Res Pract 196: 193–198. 10.1016/S0344-0338(00)80100-4.10729924
Plant, TM; Marshall, GR. (2001). The functional significance of FSH in spermatogenesis and the control of its secretion in male primates [Review]. Endocr Rev 22: 764–786. 10.1210/edrv.22.6.0446.11739331
Pontel, LB; Rosado, IV; Burgos-Barragan, G; Garaycoechea, JI; Yu, R; Arends, MJ; Chandrasekaran, G; Broecker, V; Wei, W; Liu, L; Swenberg, JA; Crossan, GP; Patel, KJ. (2015). Endogenous Formaldehyde Is a Hematopoietic Stem Cell Genotoxin and Metabolic Carcinogen. Mol Cell 60: 177–188. 10.1016/j.molcel.2015.08.020.26412304
Poon, R; Chu, I; Bjarnason, S; Vincent, R; Potvin, M; Miller, RB; Valli, VE. (1995). Short-term inhalation toxicity of methanol, gasoline, and methanol/gasoline in the rat. Toxicol Ind Health 11: 343–361. 10.1177/074823379501100305.7482574
Popa, V; Teculescu, D; Stănescu, D; Gavrilescu, N. (1969). Bronchial asthma and asthmatic bronchitis determined by simple chemicals. Dis Chest 56: 395–402.5347248
Porsolt, RD; Bertin, A; Jalfre, M. (1977). Behavioral despair in mice: a primary screening test for antidepressants. Arch Int Pharmacodyn Ther 229: 327–336.596982
Portier, CJ; Bailer, AJ. (1989). Testing for increased carcinogenicity using a survival-adjusted quantal response test. Fundam Appl Toxicol 12: 731–737. 10.1016/0272-0590(89)90004-3.2744275
Poteracki, J; Walsh, KM. (1998). Spontaneous neoplasms in control Wistar rats: A comparison of reviews. Toxicol Sci 45: 1–8. 10.1006/toxs.1998.2493.9848105
Pottern, LM; Heineman, EF; Olsen, JH; Raffn, E; Blair, A. (1992). Multiple myeloma among Danish women: Employment history and workplace exposures. Cancer Causes Control 3: 427–432. 10.1007/BF00051355.1525323
Pourmahabadian, M; Azam, K; Ghasemkhani, M. (2006). Pulmonary function study between formaldehyde exposed and non-exposed staffs at some of the Tehran educational hospitals. Journal of Medical Sciences 6: 621–625. 10.3923/jms.2006.621.625.
Prades, JM; Alaani, A; Mosnier, JF; Dumollard, JM; Martin, C. (2002). Granulocytic sarcoma of the nasal cavity. Rhinology 40: 159–161.12357718
Priha, E; Pennanen, S; Rantio, T; Uitti, J; Liesivuori, J. (2004). Exposure to and acute effects of medium-density fiber board dust. J Occup Environ Hyg 1: 738–744. 10.1080/15459620490520774.15673094
Pushkina, NN; Gofmekler, VA; Klevtsova, GN. (1968). Change in ascorbic acid and nucleic acid levels upon exposure to benzene and formaldehyde. Biull Eksp Biol Med 66: 51–53.
Qiao, Y; Li, B; Yang, G; Yao, H; Yang, J; Liu, D; Yan, Y; Sigsgaard, T; Yang, X. (2009). Irritant and adjuvant effects of gaseous formaldehyde on the ovalbumin-induced hyperresponsiveness and inflammation in a rat model. Inhal Toxicol 21: 1200–1207. 10.3109/08958370902806159.19827972
Quackenboss, JJ; Lebowitz, MD; Hayes, C. (1989a). Epidemiological study of respiratory responses to indoor/outdoor air quality. Environ Int 15: 493–502. 10.1016/0160-4120(89)90067-6.
Quackenboss, JJ; Lebowitz, MD; Hayes, C; Young, CL. (1989b). Respiratory responses to indoor/outdoor air pollutants: combustion pollutants, formaldehyde, and particulate matter.
Quackenboss, JJ; Lebowitz, MD; Michaud, JP; Bronnimann, D. (1989c). Formaldehyde exposure and acute health effects study. Environ Int 15: 169–176. 10.1016/0160-4120(89)90023-8.
Que, LG; Liu, L; Yan, Y; Whitehead, GS; Gavett, SH; Schwartz, DA; Stamler, JS. (2005). Protection from experimental asthma by an endogenous bronchodilator. Science 308: 1618–1621. 10.1126/science.1108228.15919956
Raaschou-Nielsen, O; Hermansen, MN; Loland, L; Buchvald, F; Pipper, CB; Sørensen, M; Loft, S; Bisgaard, H. (2010). Long-term exposure to indoor air pollution and wheezing symptoms in infants. Indoor Air 20: 159–167. 10.1111/j.1600-0668.2009.00635.x.20028431
Ragan, DL; Boreiko, CJ. (1981). Initiation of C3H/10T1/2 cell transformation by formaldehyde. Cancer Lett 13: 325–331. 10.1016/0304-3835(81)90061-6.7306959
Rager, JE; Moeller, BC; Doyle-Eisele, M; Kracko, D; Swenberg, JA; Fry, RC. (2013). Formaldehyde and epigenetic alterations: microRNA changes in the nasal epithelium of nonhuman primates. Environ Health Perspect 121: 339–344. 10.1289/ehp.1205582.23322811
Rager, JE; Moeller, BC; Miller, SK; Kracko, D; Doyle-Eisele, M; Swenberg, JA; Fry, RC. (2014). Formaldehyde-Associated Changes in microRNAs: Tissue and Temporal Specificity in the Rat Nose, White Blood Cells, and Bone Marrow. Toxicol Sci 138: 36–46. 10.1093/toxsci/kft267.24304932
Rager, JE; Smeester, L; Jaspers, I; Sexton, KG; Fry, RC. (2011). Epigenetic changes induced by air toxics: formaldehyde exposure alters miRNA expression profiles in human lung cells. Environ Health Perspect 119: 494–500. 10.1289/ehp.1002614.21147603
Ramirez, A; Saldanha, PH. (2002). Micronucleus investigation of alcoholic patients with oral carcinomas. Genet Mol Res 1: 246–260.14963832
Rao, GN; Piegorsch, WW; Haseman, JK. (1987). Influence of body weight on the incidence of spontaneous tumors in rats and mice of long-term studies. Am J Clin Nutr 45: 252–260.3799516
Ravault, C; Kauffmann, F. (2001). Validity of the IUATLD (1986) questionnaire in the EGEA study. Int J Tuberc Lung Dis 5: 191–196.11258514
Recio, L; Sisk, S; Pluta, L; Bermudez, E; Gross, EA; Chen, Z; Morgan, K; Walker, C. (1992). p53 mutations in formaldehyde-induced nasal squamous cell carcinomas in rats. Cancer Res 52: 6113–6116.1394239
Redlich, CA; Tarlo, SM; Hankinson, JL; Townsend, MC; Eschenbacher, WL; Von Essen, SG; Sigsgaard, T; Weissman, DN; Setting, ATSCoSitO. (2014). Official American Thoracic Society technical standards: spirometry in the occupational setting : Supplementary materials [Supplemental Data]. Am J Respir Crit Care Med 189.
Rekhadevi, PV; Mahboob, M; Rahman, MF; Grover, P. (2009). Genetic damage in wood dust-exposed workers. Mutagenesis 24: 59–65. 10.1093/mutage/gen053.18815121
Ren, X; Ji, Z; Mchale, CM; Yuh, J; Bersonda, J; Tang, M; Smith, MT; Zhang, L. (2013). The impact of FANCD2 deficiency on formaldehyde-induced toxicity in human lymphoblastoid cell lines. Arch Toxicol 87: 189–196. 10.1007/s00204-012-0911-6.22872141
Renne, R; Brix, A, my; Harkema, J; Herbert, R; Kittel, B; Lewis, D; March, T; Nagano, K; Pino, M; Rittinghausen, S; Rosenbruch, M; Tellier, P; Wohrmann, T. (2009). Proliferative and nonproliferative lesions of the rat and mouse respiratory tract. Toxicol Pathol 37: 5S–73S. 10.1177/0192623309353423.20032296
Renne, RA; Gideon, KM. (2006). Types and patterns of response in the larynx following inhalation. Toxicol Pathol 34: 281–285. 10.1080/01926230600695631.16698727
Reuzel, PGJ; Wilmer, JWG, M; Woutersen, RA; Zwart, A; Rombout, PJA; Feron, VJ. (1990). Interactive effects of ozone and formaldehyde on the nasal respiratory lining epithelium in rats. J Toxicol Environ Health 29: 279–292. 10.1080/15287399009531391.2313740
Reznik, GK. (1990). Comparative anatomy, physiology, and function of the upper respiratory tract. Environ Health Perspect 85: 171–176. 10.2307/3430681.2384061
Ridpath, JR; Nakamura, A; Tano, K; Luke, AM; Sonoda, E; Arakawa, H; Buerstedde, JM; Gillespie, DA; Sale, JE; Yamazoe, M; Bishop, DK; Takata, M; Takeda, S; Watanabe, M; Swenberg, JA; Nakamura, J. (2007). Cells deficient in the FANC/BRCA pathway are hypersensitive to plasma levels of formaldehyde. Cancer Res 67: 11117–11122. 10.1158/0008-5472.CAN-07-3028.18056434
Riedel, F; Hasenauer, E; Barth, PJ; Koziorowski, A; Rieger, CHL. (1996). Formaldehyde exposure enhances inhalative allergic sensitization in the guinea pig. Allergy 51: 94–99. 10.1111/j.1398-9995.1996.tb00041.x.8738514
Riess, U; Tegtbur, U; Fauck, C; Fuhrmann, F; Markewitz, D; Salthammer, T. (2010). Experimental setup and analytical methods for the non-invasive determination of volatile organic compounds, formaldehyde and NOx in exhaled human breath. Anal Chim Acta 669: 53–62. 10.1016/j.aca.2010.04.049.20510903
Rigby, M; O’Donnell, R; Rupniak, NM. (2005). Species differences in tachykinin receptor distribution: further evidence that the substance P (NK1) receptor predominates in human brain. J Comp Neurol 490: 335–353. 10.1002/cne.20664.16127708
Rinsky, RA; Ott, MG; Ward, E; Greenberg, HL; Halperin, W; Leet, T. (1988). Study of mortality among chemical workers in the Kanawha Valley of West Virginia. Am J Ind Med 13: 429–438. 10.1002/ajim.4700130403.3284337
Rinsky, RA; Smith, AB; Hornung, R; Filloon, TG; Young, RJ; Okun, AH; Landrigan, PJ. (1987). Benzene and leukemia. An epidemiologic risk assessment. N Engl J Med 316: 1044–1050. 10.1056/NEJM198704233161702.3561457
Ritchie, IM; Lehnen, RG. (1985). An analysis of formaldehyde concentrations in mobile and conventional homes. J Environ Health 47: 300–305.
Ritchie, IM; Lehnen, RG. (1987). Formaldehyde-related health complaints of residents living in mobile and conventional homes. Am J Public Health 77: 323–328. 10.2105/ajph.77.3.323.3812839
Roberts, DM; Yates, C; Megarbane, B; Winchester, JF; Maclaren, R; Gosselin, S; Nolin, TD; Lavergne, V; Hoffman, RS; Ghannoum, M; Group, EW. (2015). Recommendations for the role of extracorporeal treatments in the management of acute methanol poisoning: a systematic review and consensus statement [Review]. Crit Care Med 43: 461–472. 10.1097/CCM.0000000000000708.25493973
Robinson, CF; Fowler, D; Brown, DP; Lemen, RA. (1987). Plywood mill workers’ mortality patterns 1945 1977 (revised March 1987). (NIOSH/00197140). Cincinnati, OH: NIOSH.
Roda, C; Kousignian, I; Guihenneuc-Jouyaux, C; Dassonville, C; Nicolis, I; Just, J; Momas, I. (2011). Formaldehyde exposure and lower respiratory infections in infants: findings from the PARIS cohort study. Environ Health Perspect 119: 1653–1658. 10.1289/ehp.1003222.21810553
Rodrigo, R; Prat, H; Passalacqua, W; Araya, J; Guichard, C; Bächler, JP. (2007). Relationship between oxidative stress and essential hypertension. Hypertens Res 30: 1159–1167. 10.1291/hypres.30.1159.18344620
Romanazzi, V; Pirro, V; Bellisario, V; Mengozzi, G; Peluso, M; Pazzi, M; Bugiani, M; Verlato, G; Bono, R. (2013). 15-F2t isoprostane as biomarker of oxidative stress induced by tobacco smoke and occupational exposure to formaldehyde in workers of plastic laminates. Sci Total Environ 442: 20–25. 10.1016/j.scitotenv.2012.10.057.23178760
Rosado, IV; Langevin, F; Crossan, GP; Takata, M; Patel, KJ. (2011). Formaldehyde catabolism is essential in cells deficient for the Fanconi anemia DNA-repair pathway. Nat Struct Mol Biol 18: 1432–1434. 10.1038/nsmb.2173.22081012
Rothman, KJ; Boice, JD. (1979). Epidemiologic analysis with a programmable calculator. (NIH Publication No. 79-1649). Washington, D.C.: National Institutes of Health.
Rothman, KJ; Greenland, S. (1998). Modern epidemiology. In Modern Epidemiology (2 ed.). Philadelphia, PA: Lippincott-Raven.
Rothman, N; Lan, Q; Smith, MT; Vermeulen, R; Zhang, L. (2017). Response to letter to the editor of Carcinogenesis by Pira et al., 2017 [Letter]. Carcinogenesis 38: 1253–1255. 10.1093/carcin/bgx111.29040449
Roush, GC; Schymura, MJ; Stevenson, JM; Holford, TR. (1987a). Time and age trends for sinonasal cancer in Connecticut incidence and US mortality rates. Cancer 60: 422–428. 10.1002/1097-0142(19870801)60:3<422::aid-cncr2820600324>3.0.co;2-r.3594381
Roush, GC; Walrath, J; Stayner, LT; Kaplan, SA; Flannery, JT; Blair, A. (1987b). Nasopharyngeal cancer sinonasal cancer and occupations related to formaldehyde: A case-control study. J Natl Cancer Inst 79: 1221–1224.3480373
Rozhok, AI; Wahl, GM; Degregori, J. (2015). A critical examination of the “bad luck” explanation of cancer risk [Comment]. 8: 762–764. 10.1158/1940-6207.CAPR-15-0229.
Rumchev, K; Spickett, J; Bulsara, M; Phillips, M; Stick, S. (2004). Association of domestic exposure to volatile organic compounds with asthma in young children. Thorax 59: 746–751. 10.1136/thx.2003.013680.15333849
Rumchev, KB; Spickett, JT; Bulsara, MK; Phillips, MR; Stick, SM. (2002). Domestic exposure to formaldehyde significantly increases the risk of asthma in young children. Eur Respir J 20: 403–408. 10.1183/09031936.02.00245002.12212974
Rusch, GM; Clary, JJ; Rinehart, WE; Bolte, HF. (1983). A 26-week inhalation toxicity study with formaldehyde in the monkey, rat, and hamster. Toxicol Appl Pharmacol 68: 329–343. 10.1016/0041-008X(83)90276-4.6857667
Russell, NH. (1997). Biology of acute leukaemia. Lancet 349: 118–122.8996433
Russo, J; Gusterson, BA; Rogers, AE; Russo, IH; Wellings, S. R.; Van Zwieten, MJ. (1990). Comparative study of human and rat mammary tumorigenesis [Review]. Lab Invest 62: 244–278.2107367
Saberi Hosnijeh, F; Christopher, Y; Peeters, P; Romieu, I; Xun, W; Riboli, E; Raaschou-Nielsen, O; Tjønneland, A; Becker, N; Nieters, A; Trichopoulou, A; Bamia, C; Orfanos, P; Oddone, E; Luján-Barroso, L; Dorronsoro, M; Navarro, C; Barricarte, A; Molina-Montes, E; Wareham, N; Vineis, P; Vermeulen, R. (2013). Occupation and risk of lymphoid and myeloid leukaemia in the European Prospective Investigation into Cancer and Nutrition (EPIC). Occup Environ Med 70: 464–470. 10.1136/oemed-2012-101135.23576671
Sadakane, K; Takano, H; Ichinose, T; Yanagisawa, R; Shibamoto, T. (2002). Formaldehyde enhances mite allergen-induced eosinophilic inflammation in the murine airway. J Environ Pathol Toxicol Oncol 21: 267–276.12435080
Sahin-Yilmaz, A; Naclerio, RM. (2011). Anatomy and physiology of the upper airway [Review]. Proc Am Thorac Soc 8: 31–39. 10.1513/pats.201007-050RN.21364219
Saillenfait, AM; Bonnet, P; de Ceaurriz, J. (1989). The effects of maternally inhaled formaldehyde on embryonal and foetal development in rats. Food Chem Toxicol 27: 545–548. 10.1016/0278-6915(89)90051-3.2792978
Saito, Y; Nishio, K; Yoshida, Y; Niki, E. (2005). Cytotoxic effect of formaldehyde with free radicals via increment of cellular reactive oxygen species. Toxicology 210: 235–245. 10.1016/j.tox.2005.02.006.15840437
Salonen, H; Pasanen, AL; Lappalainen, S; Riuttala, H; Tuomi, T; Pasanen, P; Back, B; Reijula, K. (2009). Volatile organic compounds and formaldehyde as explaining factors for sensory irritation in office environments. J Occup Environ Hyg 6: 239–247. 10.1080/15459620902735892.19184725
Salthammer, T; Mentese, S; Marutzky, R. (2010). Formaldehyde in the indoor environment. Chem Rev 110: 2536–2572. 10.1021/cr800399g.20067232
Sandel, M; Murphy, JS; Dixon, SL; Adgate, JL; Chew, GL; Dorevitch, S; Jacobs, DE. (2014). A side-by-side comparison of three allergen sampling methods in settled house dust. J Expo Sci Environ Epidemiol 24: 650–656. 10.1038/jes.2014.30.24802556
Sandikci, M; Eren, U; Kum, S. (2007a). Effects of formaldehyde and xylene on alpha-naphthyl acetate esterase positive T-lymphocytes in bronchus associated lymphoid tissue and peripheral blood in rats. Rev Med Vet 158: 297–301.
Sandikci, M; Eren, U; Kum, S. (2007b). Effects of formaldehyde and xylene on CD4- and CD8-positive T cells in bronchus-associated lymphoid tissue in rats. Toxicol Ind Health 23: 471–477. 10.1177/0748233708089025.18669168
Santiago, LY; Hann, MC; Ben-Jebria, A; Ultman, JS. (2001). Ozone absorption in the human nose during unidirectional airflow. J Appl Physiol (1985) 91: 725–732. 10.1152/jappl.2001.91.2.725.11457787
Santovito, A; Schilirò, T; Castellano, S; Cervella, P; Bigatti, MP; Gilli, G; Bono, R; Delpero, M. (2011). Combined analysis of chromosomal aberrations and glutathione S-transferase M1 and T1 polymorphisms in pathologists occupationally exposed to formaldehyde. Arch Toxicol 85: 1295–1302. 10.1007/s00204-011-0668-3.21360194
Saowakon, N; Ngernsoungnern, P; Watcharavitoon, P; Ngernsoungnern, A; Kosanlavit, R. (2015). Formaldehyde exposure in gross anatomy laboratory of Suranaree University of Technology: a comparison of area and personal sampling. Environ Sci Pollut Res Int 22: 19002–19012. 10.1007/s11356-015-5078-2.26233735
Sapmaz, HI; Sarsılmaz, M; Gödekmerdan, A; Ögetürk, M; Taş, U; Köse, E. (2015). Effects of formaldehyde inhalation on humoral immunity and protective effect of Nigella sativa oil: An experimental study. Toxicol Ind Health 32: 1564–1569. 10.1177/0748233714566294.25653037
Sapmaz, HI; Yildiz, A; Polat, A; Vardi, N; Kose, E; Tanbek, K; Cuglan, S. (2018). Protective efficacy of Nigella sativa oil against the harmful effects of formaldehyde on rat testicular tissue. 8: 548–553. 10.4103/2221-1691.245970.
Sari, DK; Kuwahara, S; Furuya, M; Tsukamoto, Y; Hori, H; Kunugita, N; Arashidani, K; Fujimaki, H; Sasaki, F. (2005). Hypothalamo-pituitary-adrenal gland axis in mice inhaling toluene prior to low-level long-term exposure to formaldehyde. J Vet Med Sci 67: 303–309. 10.1292/jvms.67.303.15805735
Sari, DK; Kuwahara, S; Tsukamoto, Y; Hori, H; Kunugita, N; Arashidani, K; Fujimaki, H; Sasaki, F. (2004). Effect of prolonged exposure to low concentrations of formaldehyde on the corticotropin releasing hormone neurons in the hypothalamus and adrenocorticotropic hormone cells in the pituitary gland in female mice. Brain Res 1013: 107–116. 10.1016/j.brainres.2004.03.070.15196973
Sarigiannis, DA; Karakitsios, SP; Gotti, A; Liakos, IL; Katsoyiannis, A. (2011). Exposure to major volatile organic compounds and carbonyls in European indoor environments and associated health risk [Review]. Environ Int 37: 743–765. 10.1016/j.envint.2011.01.005.21354626
Sarsilmaz, M; Kaplan, S; Songur, A; Colakoglu, S; Aslan, H; Tunc, AT; Ozen, OA; Turgut, M; Baş, O. (2007). Effects of postnatal formaldehyde exposure on pyramidal cell number, volume of cell layer in hippocampus and hemisphere in the rat: A stereological study. Brain Res 11: 157–167. 10.1016/j.brainres.2007.01.139.
Sarsilmaz, M; Ozen, OA; Akpolat, N; Kus, I; Songur, A. (1999). The histopathologic effects of inhaled formaldehyde on leydig cells of the rats in subacute period. Firat Univ Med Sci J 13: 37–40.
Sauder, LR; Chatham, MD; Green, DJ; Kulle, TJ. (1986). Acute pulmonary response to formaldehyde exposure in healthy nonsmokers. J Occup Environ Med 28: 420–424. 10.1097/00043764-198606000-00008.
Sauder, LR; Green, DJ; Chatham, MD; Kulle, TJ. (1987). Acute pulmonary response of asthmatics to 3.0 ppm formaldehyde. Toxicol Ind Health 3: 569–578. 10.1177/074823378700300408.3433289
Saurel-Cubizolles, MJ; Hays, M; Estryn-Behar, M. (1994). Work in operating rooms and pregnancy outcome among nurses. Int Arch Occup Environ Health 66: 235–241. 10.1007/bf00454361.7843833
Schachter, EN; Witek, TJ, Jr; Brody, DJ; Tosun, T; Beck, GJ; Leaderer, BP. (1987). A study of respiratory effects from exposure to 2.0 ppm formaldehyde in occupationally exposed workers. Environ Res 44: 188–205. 10.1016/S0013-9351(87)80227-X.3691441
Schachter, EN; Witek, TJ, Jr; Tosun, T; Leaderer, BP; Beck, GJ. (1986). A study of respiratory effects from exposure to 2 ppm formaldehyde in healthy subjects. Arch Environ Occup Health 41: 229–239. 10.1080/00039896.1986.9938338.
Schafer, D; Brommer, C; Riechelmann, H; Mann, JW. (1999). In vivo and in vitro effect of ozone and formaldehyde on human nasal mucociliary transport system. Rhinology 37: 56–60.10416249
Schenker, MB; Weiss, ST; Murawski, BJ. (1982). Health effects of residence in homes with urea formaldehyde foam insulation: A pilot study. Environ Int 8: 359–363. 10.1016/0160-4120(82)90050-2.
Schlosser, PM. (1999). Relative roles of convection and chemical reaction for the disposition of formaldehyde and ozone in nasal mucus. Inhal Toxicol 11: 967–980. 10.1080/089583799196736.10509029
Schlosser, PM; Lilly, PD; Conolly, RB; Janszen, DB; Kimbell, JS. (2003). Benchmark dose risk assessment for formaldehyde using airflow modeling and a single-compartment, DNA-protein cross-link dosimetry model to estimate human equivalent doses. Risk Anal 23: 473–487. 10.1111/1539-6924.00328.12836840
Schoenberg, JB; Mitchell, CA. (1975). Airway disease caused by phenolic (phenol-formaldehyde) resin exposure. Arch Environ Health 30: 574–577. 10.1080/00039896.1975.10666782.128330
Schreiber, H; Bibbo, M; Wied, GL; Saccomanno, G; Nettesheim, P. (1979). Bronchial metaplasia as a benign or premalignant lesion. I. Cytologic and ultrastructural discrimination between acute carcinogen effects and toxin-induced changes. Acta Cytol 23: 496–503.295169
Schroeder, EB; Welch, VL; Couper, D; Nieto, FJ; Liao, DP; Rosamond, WD; Heiss, G. (2003). Lung function and incident coronary heart disease - The atherosclerosis risk in communities study. Am J Epidemiol 158: 1171–1181. 10.1093/aje/kwg276.14652302
Schroeter, JD; Campbell, J; Kimbell, JS; Conolly, RB; Clewell, HJ; Andersen, ME. (2014). Effects of endogenous formaldehyde in nasal tissues on inhaled formaldehyde dosimetry predictions in the rat, monkey, and human nasal passages. Toxicol Sci 138: 412–424. 10.1093/toxsci/kft333.24385418
Schuck, EA; Stephens, ER; Middleton, JT. (1966). Eye irritation response at low concentrations of irritants. Arch Environ Health 13: 570–575.5925628
Schulz, C; von Andrian, UH; Massberg, S. (2009). Hematopoietic stem and progenitor cells: their mobilization and homing to bone marrow and peripheral tissue [Review]. Immunol Res 44: 160–168. 10.1007/s12026-009-8109-6.19340403
Schunemann, HJ; Dorn, J; Grant, BJB; Winkelstein, W, Jr; Trevisan, M. (2000). Pulmonary function is a long-term predictor of mortality in the general population: 29-year follow-up of the Buffalo health study. Chest 118: 656–664. 10.1378/chest.118.3.656.10988186
SCOEL (Scientific Committee on Occupational Exposure Limits). (2017). SCOEL/REC/125 formaldehyde: recommendation from the scientific committee on occupational exposure limits.
Seals, RM; Kioumourtzoglou, MA; Gredal, O; Hansen, J; Weisskopf, MG. (2017). Occupational formaldehyde and amyotrophic lateral sclerosis. Eur J Epidemiol 32: 893–899. 10.1007/s10654-017-0249-8.28585120
Seitz, T; Baron, S. (1990). Health Hazard Evaluation Report HETA87-349-2022, Rockcastle Manufacturing, Mount Vernon, Kentucky (pp. 38). (NTIS/02970481_a). Seitz, T; Baron, S.
Sellakumar, AR; Snyder, CA; Solomon, JJ; Albert, RE. (1985). Carcinogenicity of formaldehyde and hydrogen chloride in rats. Toxicol Appl Pharmacol 81: 401–406. 10.1016/0041-008X(85)90411-9.4082190
Selvin, S; Levin, LI; Merrill, DW; Winkelstein, W, Jr. (1983). Selected epidemiologic observations of cell-specific leukemia mortality in the United States, 1969–1977. Am J Epidemiol 117: 140–152. 10.1093/oxfordjournals.aje.a113524.6829544
Sengupta, P. (2013). The laboratory rat: Relating its age with human’s [Review]. IJPM 4: 624–630.23930179
Senichenkova, II. (1991a). Embryotoxic effects of industrial environment pollutants: Formaldehyde and gasoline. Gig Sanit -: 35–38.
Senichenkova, IN. (1991b). Embryotoxic effect of formaldehyde and gasoline pollutants of industrial environment. Gig Sanit 0: 35–38.
Senichenkova, IN; Chebotar, NA. (1996a). [The effect of benzine and formaldehyde on the prenatal development of rats with induced iron trace-element disorder]. Ontogenez 27: 108–113.8725437
Senichenkova, IN; Chebotar, NA. (1996b). Effects of gasoline and formaldehyde on prenatal development of rats with induced iron micronutrient disorder (iron deficiency). Ontogenez 27: 108–113.8725437
Seow, WJ; Zhang, L; Vermeulen, R; Tang, X; Hu, W; Bassig, BA; Ji, Z; Shiels, MS; Kemp, TJ; Shen, M; Qiu, C; Reiss, B; Beane Freeman, LE; Blair, A; Kim, C; Guo, W; Wen, C; Li, L; Pinto, LA; Huang, H; Smith, MT; Hildesheim, A; Rothman, N; Lan, Q. (2015). Circulating immune/inflammation markers in Chinese workers occupationally exposed to formaldehyde. Carcinogenesis 36: 852–857. 10.1093/carcin/bgv055.25908645
Serre, K; Mohr, E; Gaspal, F; Lane, PJ; Bird, R; Cunningham, AF; Maclennan, IC. (2010). IL-4 directs both CD4 and CD8 T cells to produce Th2 cytokines in vitro, but only CD4 T cells produce these cytokines in response to alum-precipitated protein in vivo. Mol Immunol 47: 1914–1922. 10.1016/j.molimm.2010.03.010.20392496
Sexton, K; Liu, KS; Petreas, MX. (1986). Formaldehyde concentrations inside private residences: A mail-out approach to indoor air monitoring. J Air Pollut Control Assoc 36: 698–704. 10.1080/00022470.1986.10466104.3734250
Sexton, K; Petreas, MX; Liu, KS. (1989). Formaldehyde exposures inside mobile homes. Environ Sci Technol 23: 985–988. 10.1021/es00066a009.
Shaham, J; Bomstein, Y; Gurvich, R; Rashkovsky, M; Kaufman, Z. (2003). DNA-protein crosslinks and p53 protein expression in relation to occupational exposure to formaldehyde. Occup Environ Med 60: 403–409. 10.1136/oem.60.6.403.12771391
Shaham, J; Bomstein, Y; Meltzer, A; Kaufman, Z; Palma, E; Ribak, J. (1996). DNA-protein crosslinks, a biomarker of exposure to formaldehyde - in vitro and in vivo studies. Carcinogenesis 17: 121–126. 10.1093/carcin/17.1.121.8565120
Shaham, J; Bomstein, Y; Melzer, A; Ribak, J. (1997). DNA-protein crosslinks and sister chromatid exchanges as biomarkers of exposure to formaldehyde. Int J Occup Environ Health 3: 95–104. 10.1179/107735297800407695.9891106
Shangina, O; Brennan, P; Szeszenia-Dabrowska, N; Mates, D; Fabiánová, E; Fletcher, T; T’Mannetje, A; Boffetta, P; Zaridze, D. (2006). Occupational exposure and laryngeal and hypopharyngeal cancer risk in central and eastern Europe. Am J Epidemiol 164: 367–375. 10.1093/aje/kwj208.16801374
Shebl, FM; Bhatia, K; Engels, EA. (2010). Salivary gland and nasopharyngeal cancers in individuals with acquired immunodeficiency syndrome in United States [Letter]. Int J Cancer 126: 2503–2508. 10.1002/ijc.24930.19810095
Shen, H, ua; Mchale, CM; Haider, SI; Jung, C; Zhang, S; Smith, MT; Zhang, L. (2016). Identification of Genes That Modulate Susceptibility to Formaldehyde and Imatinib by Functional Genomic Screening in Human Haploid KBM7 Cells. Toxicol Sci 151: 10–22. 10.1093/toxsci/kfw032.27008852
Shenolikar, R; Song, X; Anderson, JA; Chu, BC; Cantrell, CR. (2011). Costs of asthma among US working adults. American Journal of Managed Care 17: 409–416.21756011
Sheppard, D; Eschenbacher, W; Epstein, J. (1984). Lack of bronchomotor response to up to 3 ppm formaldehyde in subjects with asthma. Environ Res 35: 133–139. 10.1016/0013-9351(84)90120-8.6489284
Sheveleva, G. (1971). Study of the specific effect of formaldehyde on the embryogenesis and progeny of white rats. Toksikol Nov Prom Khim Veshchestv 12: 78–86.
Shi, YQ; Chen, X; Dai, J; Jiang, ZF; Li, N; Zhang, BY; Zhang, ZB. (2014). Selenium pretreatment attenuates formaldehyde-induced genotoxicity in A549 cell lines. Toxicol Ind Health 30: 901–909. 10.1177/0748233712466129.23160383
Shin, YS; Takeda, K; Gelfand, EW. (2009). Understanding asthma using animal models. Allergy Asthma Immunol Res 1: 10–18. 10.4168/aair.2009.1.1.10.20224665
Shumilina, AV. (1975). [Menstrual and child-bearing functions of female workers occupationally exposed to the effects of formaldehyde]. Gig Tr Prof Zabol 18–21.
Shurin, MR; Lu, L; Kalinski, P; Stewart-Akers, AM; Lotze, MT. (1999). Th1/Th2 balance in cancer, transplantation and pregnancy [Review]. 21: 339–359.
Shusterman, D. (2007). Trigeminally-mediated health effects of air pollutants: Sources of inter-individual variability [Review]. Hum Exp Toxicol 26: 149–157. 10.1177/0960327107070550.17439917
Siemiatycki, J; Wacholder, S; Richardson, L; Dewar, R; Gérin, M. (1987). Discovering carcinogens in the occupational environment: Methods of data collection and analysis of a large case-referent monitoring system. Scand J Work Environ Health 13: 486–492.3433050
Siew, SS; Kauppinen, T; Kyyrönen, P; Heikkilä, P; Pukkala, E. (2012). Occupational exposure to wood dust and formaldehyde and risk of nasal, nasopharyngeal, and lung cancer among Finnish men. Cancer Management and Research 4: 223–232. 10.2147/CMAR.S30684.22904644
Sin, DD; Wu, LL; Man, SFP. (2005). The relationship between reduced lung function and cardiovascular mortality: a population-based study and a systematic review of the literature [Review]. Chest 127: 1952–1959. 10.1378/chest.127.6.1952.15947307
Singh, I; Raizada, RM; Chaturvedi, VN; Jain, SK. (1998). Nasal mucous ciliary clearance and olfaction in atrophic rhinitis. 50: 57–59. 10.1007/BF02996772.
Slama, R; Ballester, F; Casas, M; Cordier, S; Eggesbo, M; Iniguez, C; Nieuwenhuijsen, M; Philippat, C; Rey, S; Vandentorren, S; Vrijheid, M. (2014). Epidemiologic tools to study the influence of environmental factors on fecundity and pregnancy-related outcomes [Review]. Epidemiol Rev 36: 148–164. 10.1093/epirev/mxt011.24363355
Slikker, W, Jr; Andersen, ME; Bogdanffy, MS; Bus, JS; Cohen, SD; Conolly, RB; David, RM; Doerrer, NG; Dorman, DC; Gaylor, DW; Hattis, D; Rogers, JM; Setzer, RW; Swenberg, JA; Wallace, K. (2004). Dose-dependent transitions in mechanisms of toxicity: Case studies [Review]. Toxicol Appl Pharmacol 201: 226–294. 10.1016/j.taap.2004.06.027.15582646
Smedje, G; Norback, D. (2001). Incidence of asthma diagnosis and self-reported allergy in relation to the school environment: A four-year follow-up study in schoolchildren. Int J Tuberc Lung Dis 5: 1059–1066.11716342
Smedje, G; Norbäck, D; Edling, C. (1997). Asthma among secondary schoolchildren in relation to the school environment. Clin Exp Allergy 27: 1270–1278. 10.1046/j.1365-2222.1997.1780977.x.9420130
Smerhovsky, Z; Landa, K; Rössner, P; Brabec, M; Zudova, Z; Hola, N; Pokorna, Z; Mareckova, J; Hurychova, D. (2001). Risk of cancer in an occupationally exposed cohort with increased level of chromosomal aberrations. Environ Health Perspect 109: 41–45. 10.2307/3434919.11171523
Smerhovsky, Z; Landa, K; Rőssner, P; Juzova, D; Brabec, M; Zudova, Z; Hola, N; Zarska, H; Nevsimalova, E. (2002). Increased risk of cancer in radon-exposed miners with elevated frequency of chromosomal aberrations. Mutat Res Genet Toxicol Environ Mutagen 514: 165–176. 10.1016/S1383-5718(01)00328-X.
Smith, MT; Guyton, KZ; Gibbons, CF; Fritz, JM; Portier, CJ; Rusyn, I; Demarini, DM; Caldwell, JC; Kavlock, RJ; Lambert, PF; Hecht, SS; Bucher, J. R.; Stewart, BW; Baan, RA; Cogliano, VJ; Straif, K. (2016). Key characteristics of carcinogens as a basis for organizing data on mechanisms of carcinogenesis [Review]. Environ Health Perspect 124: 713–721. 10.1289/ehp.1509912.26600562
Smith, SM; Le Beau, MM; Huo, D; Karrison, T; Sobecks, RM; Anastasi, J; Vardiman, JW; Rowley, JD; Larson, RA. (2003). Clinical-cytogenetic associations in 306 patients with therapy-related myelodysplasia and myeloid leukemia: the University of Chicago series. Blood 102: 43–52. 10.1182/blood-2002-11-3343.12623843
Smith, SM; Vale, WW. (2006). The role of the hypothalamic-pituitary-adrenal axis in neuroendocrine responses to stress. 8: 383–395.
Snedecor, GW; Cochran, WG. (1980). Statistical methods (7th ed.). Ames, IA: Iowa State University Press.
Solet, D; Zoloth, SR; Sullivan, C; Jewett, J; Michaels, DM. (1989). Patterns of mortality in pulp and paper workers. J Occup Med 31: 627–630.2769460
Songur, A; Akpolat, N; Kus, I; Ozen, OA; Zararsiz, I; Sarsilmaz, M. (2003). The effects of the inhaled formaldehyde during the early postnatal period in the hippocampus of rats: A morphological and immunohistochemical study. Neurosci Res Commun 33: 168–178. 10.1002/nrc.10093.
Songur, A; Sarsilmaz, M; Özen, OA. (2008). The effects of inhaled formaldehyde on oxidant and antioxidant systems of rat cerebellum during the postnatal development process. Toxicol Mech Meth 18: 569–574. 10.1080/15376510701555288.
Sonnenschein, C; Soto, A, naM. (2013). The aging of the 2000 and 2011 Hallmarks of Cancer reviews: A critique. J Biosci 38: 651–663. 10.1007/s12038-013-9335-6.23938395
Sont, WN; Zielinski, JM; Ashmore, JP; Jiang, H; Krewski, D; Fair, ME; Band, PR; Létourneau, EG. (2001). First analysis of cancer incidence and occupational radiation exposure based on the National Dose Registry of Canada. Am J Epidemiol 153: 309–318. 10.1093/aje/153.4.309.11207146
Sorg, BA; Bailie, TM; Tschirgi, ML; Li, N; Wu, WR. (2001a). Exposure to repeated low-level formaldehyde in rats increases basal corticosterone levels and enhances the corticosterone response to subsequent formaldehyde. Brain Res 898: 314–320. 10.1016/S0006-8993(01)02208-9.11306018
Sorg, BA; Davidson, DL; Hochstatter, T; Sylvester, PW. (2002). Repeated cocaine decreases the avoidance response to a novel aversive stimulus in rats. Psychopharmacology 163: 9–19. 10.1007/s00213-002-1133-z.12185395
Sorg, BA; Hochstatter, T. (1999). Behavioral sensitization after repeated formaldehyde exposure in rats. Toxicol Ind Health 15: 346–355. 10.1177/074823379901500309.10416287
Sorg, BA; Swindell, S; Tschirgi, ML. (2004). Repeated low level formaldehyde exposure produces enhanced fear conditioning to odor in male, but not female, rats. Brain Res 1008: 11–19. 10.1016/j.brainres.2004.02.015.15081377
Sorg, BA; Tschirgi, ML; Swindell, S; Chen, L; Fang, J. (2001b). Repeated formaldehyde effects in an animal model for multiple chemical sensitivity [Review]. Ann N Y Acad Sci 933: 57–67. 10.1111/j.1749-6632.2001.tb05814.x.12000036
Sorg, BA; Willis, JR; Nowatka, TC; Ulibarri, C; See, RE; Westberg, HH. (1996). Proposed animal neurosensitization model for multiple chemical sensitivity in studies with formalin. Toxicology 111: 135–145. 10.1016/0300-483x(96)03371-9.8711729
Sorg, BA; Willis, JR; See, RE; Hopkins, B; Westberg, HH. (1998). Repeated low-level formaldehyde exposure produces cross-sensitization to cocaine: Possible relevance to chemical sensitivity in humans. Neuropsychopharmacology 18: 385–394. 10.1016/S0893-133X(97)00179-6.9536452
Sorlie, PD; Kannel, WB; O’Connor, G. (1989). Mortality associated with respiratory function and symptoms in advanced age: the Framingham study. Am J Respir Crit Care Med 140: 379–384. 10.1164/ajrccm/140.2.379.
Speit, G; Schmid, O; Fröhler-Keller, M; Lang, I; G, T. (2007). Assessment of local genotoxic effects of formaldehyde in humans measured by the micronucleus test with exfoliated buccal mucosa cells. Mutat Res Genet Toxicol Environ Mutagen 627: 129–135. 10.1016/j.mrgentox.2006.10.013.
Speit, G; Schütz, P; Weber, I; Ma-Hock, L; Kaufmann, W; Gelbke, HP; Durrer, S. (2011). Analysis of micronuclei, histopathological changes and cell proliferation in nasal epithelium cells of rats after exposure to formaldehyde by inhalation. Mutat Res 721: 127–135. 10.1016/j.mrgentox.2011.01.008.21272661
Speit, G; Zeller, J; Schmid, O; Elhajouji, A; Ma-Hock, L; Neuss, S. (2009). Inhalation of formaldehyde does not induce systemic genotoxic effects in rats. Mutat Res Genet Toxicol Environ Mutagen 677: 76–85. 10.1016/j.mrgentox.2009.05.020.
Sripaiboonkij, P; Sripaiboonkij, N; Phanprasit, W; Jaakkola, MS. (2009). Respiratory and skin health among glass microfiber production workers: a cross-sectional study. Environ Health 8: 36. 10.1186/1476-069X-8-36.19689806
Staab, CA; Hellgren, M; Höög, JO. (2008). Dual functions of alcohol dehydrogenase 3: Implications with focus on formaldehyde dehydrogenase and S-nitrosoglutathione reductase activities [Review]. Cell Mol Life Sci 65: 3950–3960. 10.1007/s00018-008-8592-2.19011746
Starr, TB; Swenberg, JA. (2013). A novel bottom-up approach to bounding low-dose human cancer risks from chemical exposures. Regul Toxicol Pharmacol 65: 311–315. 10.1016/j.yrtph.2013.01.004.23352840
Starr, TB; Swenberg, JA. (2014). Response to Crump et al [Letter]. Regul Toxicol Pharmacol 70: 737–738. 10.1016/j.yrtph.2014.10.007.25455228
Starr, TB; Swenberg, JA. (2016). The bottom-up approach to bounding potential low-dose cancer risks from formaldehyde: An update. Regul Toxicol Pharmacol 77: 167–174. 10.1016/j.yrtph.2016.01.021.26851508
Stayner, L; Smith, AB; Reeve, G; Blade, L; Elliott, L; Keenlyside, R; Halperin, W. (1985). Proportionate mortality study of workers in the garment industry exposed to formaldehyde. Am J Ind Med 7: 229–240.3985015
Stayner, LT; Elliott, L; Blade, L; Keenlyside, R; Halperin, W. (1988). A retrospective cohort mortality study of workers exposed to formaldehyde in the garment industry. Am J Ind Med 13: 667–681. 10.1002/ajim.4700130606.3389362
Steele, LL; Wilkins, J. R. (1996). Occupational exposures and risks of spontaneous abortion among female veterinarians. Int J Occup Environ Health 2: 26–36.9933862
Stellman, SD; Demers, PA; Colin, D; Boffetta, P. (1998). Cancer mortality and wood dust exposure among participants in the American Cancer Society Cancer Prevention Study-II (CPS-II). Am J Ind Med 34: 229–237. 10.1002/(SICI)1097-0274(199809)34:3<229::AID-AJIM4>3.0.CO;2-Q.9698991
Stewart, PA; Blair, A; Cubit, DA; Bales, RE; Kaplan, SA; Ward, J; Gaffey, W; O’Berg, MT; Walrath, J. (1986). Estimating historical exposures to formaldehyde in a retrospective mortality study. Appl Ind Hyg 1: 34–41.
Stewart, PA; Cubit, D; Blair, A. (1987). Formaldehyde levels in seven industries. Appl Ind Hyg 2: 231–236.
Stewart, PA; Herrick, RF; Feigley, CE; Utterback, DF; Hornung, R; Mahar, H; Hayes, R; Douthit, DE; Blair, A. (1992). Study design for assessing exposures of embalmers for a case-control study. Part I. Monitoring results. Appl Occup Environ Hyg 7: 532–540.
Stock, TH. (1987). Formaldehyde concentrations inside conventional housing. J Air Waste Manag Assoc 37: 913–918. 10.1080/08940630.1987.10466284.
Stroup, NE; Blair, A; Erikson, GE. (1986). Brain cancer and other causes of death in anatomists. J Natl Cancer Inst 77: 1217–1224.3467114
Stücker, I; Mandereau, L; Hémon, D. (1993). Relationship between birthweight and occupational exposure to cytostatic drugs during or before pregnancy. Scand J Work Environ Health 19: 148–153. 10.5271/sjweh.1488.8367691
Subramaniam, RP; Chen, C; Crump, KS; Devoney, D; Fox, JF; Portier, CJ; Schlosser, PM; Thompson, CM; White, P. (2008). Uncertainties in biologically-based modeling of formaldehyde-induced respiratory cancer risk: Identification of key issues. Risk Anal 28: 907–923. 10.1111/j.1539-6924.2008.01083.x.18564991
Subramaniam, RP; Crump, KS; Van Landingham, C; White, P; Chen, C; Schlosser, PM. (2007). Uncertainties in the CIIT model for formaldehyde-induced carcinogenicity in the rat: A limited sensitivity analysis–I. Risk Anal 27: 1237–1254. 10.1111/j.1539-6924.2007.00968.x.18076493
Subramaniam, RP; Richardson, RB; Morgan, KT; Kimbell, JS; Guilmette, RA. (1998). Computational fluid dynamics simulations of inspiratory airflow in the human nose and nasopharynx. Inhal Toxicol 10: 91–120. 10.1080/089583798197772.
Sul, D; Kim, H; Oh, E; Phark, S; Cho, E; Choi, S; Kang, HS; Kim, EM; Hwang, KW; Jung, WW. (2007). Gene expression profiling in lung tissues from rats exposed to formaldehyde. Arch Toxicol 81: 589–597. 10.1007/s00204-007-0182-9.17285311
Summers, RM; Louie, T; Yu, C; Gakhar, L; Louie, KC; Subramanian, M. (2012). Novel, Highly Specific N-Demethylases Enable Bacteria To Live on Caffeine and Related Purine Alkaloids. J Bacteriol 194: 2041–2049. 10.1128/JB.06637-11.22328667
Suruda, A; Schulte, P; Boeniger, M; Hayes, RB; Livingston, GK; Steenland, K; Stewart, P; Herrick, R; Douthit, D; Fingerhut, MA. (1993). Cytogenetic effects of formaldehyde exposure in students of mortuary science. Cancer Epidemiol Biomarkers Prev 2: 453–460.8220090
Swenberg, J; Kerns, W; Pavkov, K; Mitchell, R; Gralla, EJ. (1980a). Carcinogenicity of formaldehyde vapor: interim findings in a long-term bioassay of rats and mice. Dev Toxicol Environ Sci 8: 283–286.7308029
Swenberg, JA; Gross, EA; Randall, HW. (1986). Localization and quantitation of cell proliferation following exposure to nasal irritants. In CS Barrow (Ed.), Toxicology of the nasal passages (pp. 291–300). New York, NY: Hemisphere Publishing Corp.
Swenberg, JA; Gross, EA; Randall, HW; Barrow, CS. (1983). The effect of formaldehyde exposure on cytotoxicity and cell proliferation. In JJ Clary; JE Gibson; RS Waritz (Eds.), Formaldehyde, toxicology, epidemiology, mechanisms (pp. 225–236). New York, NY: Marcel Dekker.
Swenberg, JA; Kerns, WD; Mitchell, RI; Gralla, EJ; Pavkov, KL. (1980b). Induction of squamous cell carcinomas of the rat nasal cavity by inhalation exposure to formaldehyde vapor. Cancer Res 40: 3398–3402.7427950
Swenberg, JA; Lu, K; Moeller, BC; Gao, L; Upton, PB; Nakamura, J; Starr, TB. (2011). Endogenous versus exogenous DNA adducts: Their role in carcinogenesis, epidemiology, and risk assessment [Review]. Toxicol Sci 120: S130–S145. 10.1093/toxsci/kfq371.21163908
Swenberg, JA; Moeller, BC; Lu, K; Rager, JE; Fry, RC; Starr, TB. (2013). Formaldehyde carcinogenicity research: 30 years and counting for mode of action, epidemiology, and cancer risk assessment [Review]. Toxicol Pathol 41: 181–189. 10.1177/0192623312466459.23160431
Swiecichowski, AL; Long, KJ; Miller, ML; Leikauf, GD. (1993). Formaldehyde-induced airway hyperreactivity in vivo and ex vivo in guinea pigs. Environ Res 61: 185–199. 10.1006/enrs.1993.1063.8495661
Taffet, GE; Donohue, JF; Altman, PR. (2014). Considerations for managing chronic obstructive pulmonary disease in the elderly [Review]. Clinical Interventions in Aging 9: 23–30. 10.2147/CIA.S52999.24376347
Takahashi, S; Tsuji, K; Fujii, K; Okazaki, F; Takigawa, T; Ohtsuka, A; Iwatsuki, K. (2007). Prospective study of clinical symptoms and skin test reactions in medical students exposed to formaldehyde gas. J Dermatol 34: 283–289. 10.1111/j.1346-8138.2007.00274.x.17408435
Takayama, S; Reed, JC; Homma, S. (2003). Heat-shock proteins as regulators of apoptosis [Review]. Oncogene 22: 9041–9047. 10.1038/sj.onc.1207114.14663482
Takigawa, T; Usami, M; Yamasaki, Y; Wang, B; Sakano, N; Horike, T; Kataoka, H; Ohtsuka, A; Kira, S. (2005). Reduction of indoor formaldehyde concentrations and subjective symptoms in a gross anatomy laboratory. Bull Environ Contam Toxicol 74: 1027–1033. 10.1007/s00128-005-0683-2.16158836
Talibov, M; Lehtinen-Jacks, S; Martinsen, JI; Kjærheim, K; Lynge, E; Sparén, P; Tryggvadottir, L; Weiderpass, E; Kauppinen, T; Kyyrönen, P; Pukkala, E. (2014). Occupational exposure to solvents and acute myeloid leukemia: A population-based, case-control study in four Nordic countries. Scand J Work Environ Health 40: 511–517. 10.5271/sjweh.3436.24840289
Tan, T; Zhang, Y; Luo, W; Lv, J; Han, C; Hamlin, JNR; Luo, H; Li, H; Wan, Y; Yang, X; Song, W; Tong, Z. (2018). Formaldehyde induces diabetes-associated cognitive impairments. FASEB J 32: 3669–3679. 10.1096/fj.201701239R.29401634
Tang, LX; Zhang, YS. (2003). [Health investigation on workers exposed to formaldehyde] (pp. 34–35). Tang, LX; Zhang, YS.
Tani, T; Kogi, K; Horiguchi, Y. (1986). Inhibitory effects of formaldehyde inhalation on the cardiovascular and respiratory systems in unanesthetized rabbits. Jpn J Pharmacol 40: 551–559. 10.1254/jjp.40.551.3735804
Tanveer, H; Rastogi, SK; Mathur, N; Gupta, BN. (1995). Respiratory responses of paper mill workers occupationally exposed to formaldehyde. Indian J Indust Med 41: 2–8.
Tarkowski, M; Gorski, P. (1995). Increased IgE antiovalbumin level in mice exposed to formaldehyde. Int Arch Allergy Immunol 106: 422–424. 10.1159/000236876.7719158
Taskinen, H; Kyyronen, P; Hemminki, K. (1994). Laboratory work and pregnancy outcome. J Occup Med 36: 311–319. 10.1097/00043764-199403000-00008.8195901
Taskinen, HK; Kyyronen, P; Sallmen, M; Virtanen, SV; Liukkonen, TA; Huida, O; Lindbohm, ML; Anttila, A. (1999). Reduced fertility among female wood workers exposed to formaldehyde. Am J Ind Med 36: 206–212. 10.1002/(sici)1097-0274(199907)36:1<206::aid-ajim29>3.0.co;2-d.10361608
Tavernier, G; Fletcher, G; Gee, I; Watson, A; Blacklock, G; Francis, H; Fletcher, A; Frank, T; Frank, P; Pickering, CA; Niven, R. (2006). IPEADAM study: Indoor endotoxin exposure, family status, and some housing characteristics in English children. J Allergy Clin Immunol 117: 656–662. 10.1016/j.jaci.2005.12.1311.16522467
ten Berge, WF; Zwart, A; Appelman, LM. (1986). Concentration-time mortality response relationship of irritant and systemically acting vapours and gases. J Hazard Mater 13: 301–309. 10.1016/0304-3894(86)85003-8.
Teng, S; Beard, K; Pourahmad, J; Moridani, M; Easson, E; Poon, R; O’Brien, PJ. (2001). The formaldehyde metabolic detoxification enzyme systems and molecular cytotoxic mechanism in isolated rat hepatocytes. Chem Biol Interact 130–132: 285–296. 10.1016/S0009-2797(00)00272-6.
Tepper, JS; Moser, VC; Costa, DL; Mason, MA; Roache, N; Guo, Z; Dyer, RS. (1995). Toxicological and chemical evaluation of emissions from carpet samples. Am Ind Hyg Assoc J 56: 158–170. 10.1080/15428119591017196.7856517
Tepper, RS; Wise, RS; Covar, R; Irvin, CG; Kercsmar, CM; Kraft, M; Liu, MC; O’Connor, GT; Peters, SP; Sorkness, R; Togias, A. (2012). Asthma outcomes: Pulmonary physiology [Review]. J Allergy Clin Immunol 129: S65–S87. 10.1016/j.jaci.2011.12.986.22386510
Teschke, K; Morgan, MS; Checkoway, H; Franklin, G; Spinelli, JJ; van Belle, G; Weiss, NS. (1997). Surveillance of nasal and bladder cancer to locate sources of exposure to occupational carcinogens. Occup Environ Med 54: 443–451. 10.1136/oem.54.6.443.9245952
Thompson, CM; Ceder, R; Grafström, RC. (2010). Formaldehyde dehydrogenase: beyond phase I metabolism. Toxicol Lett 193: 1–3. 10.1016/j.toxlet.2009.11.023.19963048
Thompson, CM; Sonawane, B; Grafstrom, RC. (2009). The ontogeny, distribution, and regulation of alcohol dehydrogenase 3: Implications for pulmonary physiology [Review]. Drug Metab Dispos 37: 1565–1571. 10.1124/dmd.109.027904.19460944
Thrasher, JD; Broughton, A; Madison, R. (1990). Immune activation and autoantibodies in humans with long-term inhalation exposure to formaldehyde. Arch Environ Health 45: 217–223. 10.1080/00039896.1990.9940805.2400243
Thrasher, JD; Wojdani, A; Cheung, G; Heuser, G. (1987). Evidence for formaldehyde antibodies and altered cellular immunity in subjects exposed to formaldehyde in mobile homes. Arch Environ Health 42: 347–350. 10.1080/00039896.1987.9934357.3439811
Thun, MJ; Lakat, M; Altman, R. (1982). Symptom survey of residents of homes insulated with ureaformaldehyde foam. Environ Res 29: 320–334. 10.1016/0013-9351(82)90034-2.6926753
Til, HP; Woutersen, RA; Feron, VJ; Hollanders, VHM; Falker, HE; Clary, JJ. (1989). Two-year drinking-water study of formaldehyde in rats. Food Chem Toxicol 27: 77–87. 10.1016/0278-6915(89)90001-X.2714719
Titenko-Holland, N; Levine, AJ; Smith, MT; Quintana, PJ; Boeniger, M; Hayes, R; Suruda, A; Schulte, P. (1996). Quantification of epithelial cell micronuclei by fluorescence in situ hybridization (FISH) in mortuary science students exposed to formaldehyde. Mutat Res 371: 237–248. 10.1016/S0165-1218(96)90112-3.9008725
Tobe, M; Kaneko, Y; Uchida, Y; . (1985). Studies of the inhalation toxicity of formaldehyde. National Sanitary and Medical Laboratory Service, Toxicity, Tokyo, Japan; T-85-0236. Tobe, M; Kaneko, Y; Uchida, Y; .
Togias, A. (1999). Mechanisms of nose-lung interaction [Review]. Allergy 54: 94–105. 10.1111/j.1398-9995.1999.tb04410.x.10565484
Togias, A. (2004). Systemic effects of local allergic disease [Review]. J Allergy Clin Immunol 113: S8–14. 10.1016/j.jaci.2003.09.051.14694344
Tomasetti, C; Vogelstein, B. (2015). Variation in cancer risk among tissues can be explained by the number of stem cell divisions. Science 347: 78–81. 10.1126/science.1260825.25554788
Tomashefski, J. (2008). Dail and Hammar’s pulmonary pathology: Neoplastic lung disease. In J Tomashefski (Ed.), (3rd ed., pp. 165–182). New York, NY: Springer.
Tong, ZM; Zhu, SX; Shi, J. (2007). [Effect of formaldehyde on blood component and blood biochemistry of exposed workers]. 20: 409–410.
Torjussen, W; Solberg, LA; Hogetveit, AC. (1979). Histopathological changes of the nasal mucosa in active and retired nickel workers. Br J Cancer 40: 568–580.497107
Tsigonia, A; Lagoudi, A; Chandrinou, S; Linos, A; Evlogias, N; Alexopoulos, EC. (2010). Indoor air in beauty salons and occupational health exposure of cosmetologists to chemical substances. Int J Environ Res Public Health 7: 314–324. 10.3390/ijerph7010314.20195448
Tsubone, H; Kawata, M. (1991). Stimulation to the trigeminal afferent nerve of the nose by formaldehyde, acrolein, and acetaldehyde gases. Inhal Toxicol 3: 211–222. 10.3109/08958379109145285.
Tsukahara, S; Yamamoto, S; Shwe, TTW; Ahmed, S; Kunugita, N; Arashidani, K; Fujimaki, H. (2006). Inhalation of low-level formaldehyde increases the Bcl-2/Bax expression ratio in the hippocampus of immunologically sensitized mice. Neuroimmunomodulation 13: 63–68. 10.1159/000094829.16888403
Tunc, O; Tremellen, K. (2009). Oxidative DNA damage impairs global sperm DNA methylation in infertile men. J Assist Reprod Genet 26: 537–544. 10.1007/s10815-009-9346-2.19876730
Turner, JH; Reh, DD. (2012). Incidence and survival in patients with sinonasal cancer: A historical analysis of population-based data. Head Neck 34: 877–885. 10.1002/hed.21830.22127982
Tyihák, E; Bocsi, J; Timár, F; Rácz, G; Szende, B. (2001). Formaldehyde promotes and inhibits the proliferation of cultured tumour and endothelial cells. Cell Prolif 34: 135–141. 10.1046/j.1365-2184.2001.00206.x.11380483
U.S. EPA (U.S. Environmental Protection Agency). (1989). Lymphatic and hematopoietic tissue cancer in a chemcial MFG environment and a mortality study of men assigned to ethylene oxide production or other related chemical MFG w-letter 081789 [TSCA Submission]. (EPA/OTS; Doc #89-890000225). Danbury, CT: Union Carbide Corporation. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS05134143.xhtml.
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1998). Guidelines for neurotoxicity risk assessment [EPA Report]. (EPA/630/R-95/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/risk/guidelines-neurotoxicity-risk-assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2000). Benchmark dose software version 12 [Computer Program].
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2003). Summary of the toxicological review of acrolein [EPA Report]. Washington, DC. https://cfpub.epa.gov/ncea/iris2/chemicalLanding.cfm?substance_nmbr=364.
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens [EPA Report]. (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/supplemental-guidance-assessing-susceptibility-early-life-exposure-carcinogens.
U.S. EPA (U.S. Environmental Protection Agency). (2010). Toxicological Review of Formaldehyde (Inhalation) (External Review Draft 2010). http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=223614.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2013). Toxicological review of Methanol (Noncancer) (CASRN 67-56-1) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-11-001F). Washington, DC. https://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100GZGY.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2017). Categorical regression (CATREG) user guide, version 3.1.0.7. BMDS. https://www.epa.gov/sites/production/files/2016-03/documents/catreg_user_guide.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2020). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA600R20137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
Uba, G; Pachorek, D; Bernstein, J; Garabrant, DH; Balmes, JR; Wright, WE; Amar, RB. (1989). Prospective study of respiratory effects of formaldehyde among healthy and asthmatic medical students. Am J Ind Med 15: 91–101. 10.1002/ajim.4700150110.2929612
Usanmaz, SE; Akarsu, ES; Vural, N. (2002). Neurotoxic effects of acute and subacute formaldehyde exposures in mice. Environ Toxicol Pharmacol 11: 93–100. 10.1016/S1382-6689(01)00109-0.21782590
Vaissière, T; Sawan, C; Herceg, Z. (2008). Epigenetic interplay between histone modifications and DNA methylation in gene silencing [Review]. Mutat Res 659: 40–48. 10.1016/j.mrrev.2008.02.004.18407786
Valencia, K; Martín-Fernández, M; Zandueta, C; Ormazábal, C; Martínez-Canarias, S; Bandrés, E; de la Piedra, C; Lecanda, F. (2013). miR-326 associates with biochemical markers of bone turnover in lung cancer bone metastasis. Bone 52: 532–539. 10.1016/j.bone.2012.10.033.23142363
Valverde, M; Rojas, E. (2009). Environmental and occupational biomonitoring using the Comet assay [Review]. Mutat Res Rev Mutat Res 681: 93–109. 10.1016/j.mrrev.2008.11.001.
Vandenplas, O; Fievez, P; Delwiche, JP; Boulanger, J; Thimpont, J. (2004). Persistent asthma following accidental exposure to formaldehyde. Allergy 59: 115–116. 10.1046/j.1398-9995.2003.00340.x.14674947
Vaughan, TL. (1989). Occupation and squamous cell cancers of the pharynx and sinonasal cavity. Am J Ind Med 16: 493–510. 10.1002/ajim.4700160503.2589327
Vaughan, TL. (1996). Agents causing other respiratory cancers. In Occupational and environmental respiratory disease. St. Louis, MO: Mosby-Year Book, Inc.
Vaughan, TL; Davis, S. (1991). Wood dust exposure and squamous cell cancers of the upper respiratory tract. Am J Epidemiol 133: 560–564. 10.1093/oxfordjournals.aje.a115927.2006642
Vaughan, TL; Stewart, PA; Teschke, K; Lynch, CF; Swanson, GM; Lyon, JL; Berwick, M. (2000). Occupational exposure to formaldehyde and wood dust and nasopharyngeal carcinoma. Occup Environ Med 57: 376–384. 10.1136/oem.57.6.376.10810126
Vaughan, TL; Strader, C; Davis, S; Daling, JR. (1986a). Formaldehyde and cancers of the pharynx, sinus and nasal cavity: I. Occupational exposures. Int J Cancer 38: 677–683. 10.1002/ijc.2910380510.3770995
Vaughan, TL; Strader, C; Davis, S; Daling, JR. (1986b). Formaldehyde and cancers of the pharynx, sinus and nasal cavity: II. Residential exposures. Int J Cancer 38: 685–688. 10.1002/ijc.2910380511.3770996
Venn, A. (2012). [Email to Glinda Cooper concerning FW: Follow-up question regarding 2003 wheeze study].
Venn, AJ; Cooper, M; Antoniak, M; Laughlin, C; Britton, J; Lewis, SA. (2003). Effects of volatile organic compounds, damp, and other environmental exposures in the home on wheezing illness in children. Thorax 58: 955–960. 10.1136/thorax.58.11.955.14586048
Veres, TZ; Rochlitzer, S; Braun, A. (2009). The role of neuro-immune cross-talk in the regulation of inflammation and remodelling in asthma [Review]. Pharmacol Ther 122: 203–214. 10.1016/j.pharmthera.2009.02.007.19292991
Viegas, S; Ladeira, C; Nunes, C; Malta-Vacas, J; Gomes, M; Brito, M; Mendonca, P; Prista, J. (2010). Genotoxic effects in occupational exposure to formaldehyde: A study in anatomy and pathology laboratories and formaldehyde-resins production. J Occup Med Toxicol 5: 25. 10.1186/1745-6673-5-25.20727169
Villeneuve, DL; Crump, D; Garcia-Reyero, N; Hecker, M; Hutchinson, TH; Lalone, CA; Landesmann, B; Lettieri, T; Munn, S; Nepelska, M; Ottinger, MA; Vergauwen, L; Whelan, M. (2014). Adverse outcome pathway (AOP) development I: Strategies and principles. Toxicol Sci 142: 312–320. 10.1093/toxsci/kfu199.25466378
Vlaanderen, J; Lan, Q; Kromhout, H; Rothman, N; Vermeulen, R. (2011). Occupational benzene exposure and the risk of lymphoma subtypes: a meta-analysis of cohort studies incorporating three study quality dimensions [Review]. Environ Health Perspect 119: 159–167. 10.1289/ehp.1002318.20880796
Vokes, EE; Weichselbaum, RR; Lippman, SM; Hong, WK. (1993). Head and neck cancer [Review]. N Engl J Med 328: 184–194. 10.1056/NEJM199301213280306.8417385
von Kobyletzki, LB; Berner, A; Carlstedt, F; Hasselgren, M; Bornehag, CG; Svensson, A. (2013). Validation of a parental questionnaire to identify atopic dermatitis in a population-based sample of children up to 2 years of age. Dermatology 226: 222–226. 10.1159/000349983.23796755
Vosoughi, S; Khavanin, A; Salehnia, M; Asilian Mahabadi, H; Shahverdi, A; Esmaeili, V. (2013). Adverse effects of formaldehyde vapor on mouse sperm parameters and testicular tissue. Int J Fertility Sterility 6: 250–257.
Vosoughi, S; Khavanin, A; Salehnia, M; Mahabadi, HA; Soleimanian, A. (2012). Effects of simultaneous exposure to formaldehyde vapor and noise on mouse testicular tissue and sperm parameters. Health Scope 1: 110–117. 10.17795/jhealthscope-7973.
Wallner, P; Kundi, M; Moshammer, H; Piegler, K; Hohenblum, P; Scharf, S; Fröhlich, M; Damberger, B; Tapplere, P; Hutter, HP. (2012). Indoor air in schools and lung function of Austrian school children. J Environ Monit 14: 1976–1982. 10.1039/c2em30059a.22652689
Walrath, J; Fraumeni, JF, Jr. (1983). Mortality patterns among embalmers. Int J Cancer 31: 407–411. 10.1002/ijc.2910310403.6832852
Walrath, J; Fraumeni, JF, Jr. (1984). Cancer and other causes of death among embalmers. Cancer Res 44: 4638–4641.6467219
Walsh, DA; Edwards, MJ; Smith, MSR. (1997). Heat shock proteins and their role in early mammalian development. Exp Mol Med 29: 139–150. 10.1038/emm.1997.21.
Wang, F, an; Li, C; Liu, W, ei; Jin, Y. (2014a). Potential mechanisms of neurobehavioral disturbances in mice caused by sub-chronic exposure to low-dose VOCs. Inhal Toxicol 26: 250–258. 10.3109/08958378.2014.882447.24568580
Wang, H; Li, H, eC; Lv, M; Zhou, D; Bai, L; Du, L; Xue, X, ia; Lin, P, u; Qiu, S. (2015). Associations between occupation exposure to Formaldehyde and semen quality, a primary study. Sci Rep 5: 15874. 10.1038/srep15874.26515386
Wang, H; O’Reilly, ÉJ; Weisskopf, MG; Logroscino, G; Mccullough, ML; Thun, MJ; Schatzkin, A; Kolonel, LN; Ascherio, A. (2011). Smoking and risk of amyotrophic lateral sclerosis: a pooled analysis of 5 prospective cohorts. Arch Neurol 68: 207–213. 10.1001/archneurol.2010.367.21320987
Wang, HX; Wang, XY; Zhou, DX; Zheng, LR; Zhang, J; Huo, YW; Tian, H. (2013). Effects of low-dose, long-term formaldehyde exposure on the structure and functions of the ovary in rats. Toxicol Ind Health 29: 609–615. 10.1177/0748233711430983.22287616
Wang, HX; Zhou, DX; Zheng, LR; Zhang, J; Huo, YW; Tian, H; Han, SP; Zhang, J; Zhao, WB. (2012). Effects of paternal occupation exposure to formaldehyde on reproductive outcomes. J Occup Environ Med 54: 518–524. 10.1097/JOM.0b013e31824e6937.22576458
Wang, K; Wang, TW; Xu, J; Zhu, Y; Jian, L; Au, W; Xia, ZL. (2019). Determination of benchmark dose based on adduct and micronucleus formations in formaldehyde-exposed workers. Int J Hyg Environ Health 222: 738–743. 10.1016/j.ijheh.2019.05.008.31147150
Wang, R; Zhang, Y; Lan, Q; Holford, TR; Leaderer, B; Zahm, SH; Boyle, P; Dosemeci, M; Rothman, N; Zhu, Y; Qin, Q; Zheng, T. (2009). Occupational exposure to solvents and risk of non-Hodgkin lymphoma in Connecticut women. Am J Epidemiol 169: 176–185. 10.1093/aje/kwn300.19056833
Wang, W; Yan, Y; Li, CW; Xia, HM; Chao, SS; Wang, d; Wang, ZP. (2014b). Live human nasal epithelial cells (hNECs) on chip for in vitro testing of gaseous formaldehyde toxicity via airway delivery. Lab Chip 14: 677–680. 10.1039/c3lc51208h.24356185
Wantke, F; Demmer, CM; Tappler, P; Gotz, M; Jarisch, R. (1996a). Exposure to gaseous formaldehyde induces IgE-mediated sensitization to formaldehyde in school-children. Clin Exp Allergy 26: 276–280. 10.1111/j.1365-2222.1996.tb00092.x.8729664
Wantke, F; Focke, M; Hemmer, W; Bracun, R; Wolf-Abdolvahab, S; Götz, M; Jarisch, R; Götz, M; Tschabitscher, M; Gann, M; Tappler, P. (2000). Exposure to formaldehyde and phenol during an anatomy dissecting course: Sensitizing potency of formaldehyde in medical students. Allergy 55: 84–87. 10.1034/j.1398-9995.2000.00307.x.10696862
Wantke, F; Focke, M; Hemmer, W; Tschabitscher, M; Gann, M; Tappler, P; Götz, M; Jarisch, R. (1996b). Formaldehyde and phenol exposure during an anatomy dissection course: A possible source of IgE-mediated sensitization. Allergy 51: 837–841. 10.1111/j.1398-9995.1996.tb00031.x.8947343
Ward, JB, Jr; Hokanson, JA; Smith, ER; Chang, LW; Pereira, MA; Whorton, EB, Jr; Legator, MS. (1984). Sperm count, morphology and fluorescent body frequency in autopsy service workers exposed to formaldehyde. Mutat Res Environ Mutagen Relat Subj 130: 417–424. 10.1016/0165-1161(84)90014-1.
Warner, JK; Wang, JC; Hope, KJ; Jin, L; Dick, JE. (2004). Concepts of human leukemic development [Review]. Oncogene 23: 7164–7177. 10.1038/sj.onc.1207933.15378077
Weatherhead, S; Robson, SC; Reynolds, NJ. (2007). Eczema in pregnancy [Review]. BMJ 335: 152–154. 10.1136/bmj.39227.671227.AE.17641349
Wei, CN; Harada, K; Ohmori, S; Wei, QJ; Minamoto, K; Ueda, A. (2007). Subjective symptoms of medical students exposed to formaldehyde during a gross anatomy dissection course. Int J Immunopathol Pharmacol 20: 23–25. 10.1177/03946320070200S205.
Weidinger, S; Novak, N. (2016a). Atopic dermatitis [Review]. Lancet 387: 1109–1122. 10.1016/S0140-6736(15)00149-X.26377142
Weidinger, S; Novak, N. (2016b). Atopic dermatitis : Supplementary materials [Supplemental Data]. Lancet 387.
Weinberg, RA. (2014). Coming full circle-from endless complexity to simplicity and back again [Review]. Cell 157: 267–271. 10.1016/j.cell.2014.03.004.24679541
Weisel, CP; Zhang, J; Turpin, BJ; Morandi, MT; Colome, S; Stock, TH; Spektor, DM; Korn, L; Winer, AM; Kwon, J; Meng, QY; Zhang, L; Harrington, R; Liu, W; Reff, A; Lee, JH; Alimokhtari, S; Mohan, K; Shendell, D; Jones, J; Farrar, L; Maberti, S; Fan, T. (2005). Relationships of indoor, outdoor, and personal air (RIOPA): Part I. Collection methods and descriptive analyses (pp. 1–107; discussion 109-127). (ISSN 1041-5505 EISSN 2688-6855 HEI Research Report 130-I, NUATRC Research Report 7). Boston, MA: Health Effects Institute. https://www.proquest.com/scholarly-journals/relationships-indoor-outdoor-personal-air-riopa/docview/70114572/se-2?accountid=171501.
Weisskopf, M; Morozova, N; O’Reilly, EJ; Mccullough, ML; Calle, EE; Thun, MJ; Ascherio, A. (2009). Prospective study of chemical exposures and amyotrophic lateral sclerosis mortality. J Neurol Neurosurg Psychiatry 80: 558–561. 10.1136/jnnp.2008.156976.19372290
Wells, PG; Winn, LM. (1996). Biochemical toxicology of chemical teratogenesis. Crit Rev Biochem Mol Biol 31: 1–40. 10.3109/10409239609110574.8744954
Werner, A; Meinhardt, A; Seitz, J; Bergmann, M. (1997). Distribution of heat-shock protein 60 immunoreactivity in testes of infertile men. Cell Tissue Res 288: 539–544. 10.1007/s004410050839.9134866
Wesseling, C; Ahlbom, A; Antich, D; Rodriguez, AC; Castro, R. (1996). Cancer in banana plantation workers in Costa Rica. Int J Epidemiol 25: 1125–1131. 10.1093/ije/25.6.1125.9027515
West, GB; Brown, JH. (2005). The origin of allometric scaling laws in biology from genomes to ecosystems: Towards a quantitative unifying theory of biological structure and organization [Review]. J Exp Biol 208: 1575–1592. 10.1242/jeb.01589.15855389
West, S; Hildesheim, A; Dosemeci, M. (1993). Non-viral risk factors for nasopharyngeal carcinoma in the Philippines: Results from a case-control study. Int J Cancer 55: 722–727. 10.1002/ijc.2910550504.7503957
WHO (World Health Organization). (1967). Manual of the international statistical classification of diseases, injuries, and causes of death. Geneva, Switzerland.
WHO (World Health Organization). (1977). Manual of the international statistical classification of diseases, injuries, and causes of death. Geneva, Switzerland.
WHO (World Health Organization). (2010). Guidelines for indoor air quality: Selected pollutants. Geneva. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf.
Widdicombe, JG. (1998). Afferent receptors in the airways and cough [Review]. Respir Physiol 114: 5–15.9858046
Wilcox, AJ. (2010). Fertility and pregnancy: An epidemiologic perspective. In Fertility and pregnancy: An epidemiologic perspective. New York, NY: Oxford University Press.
Wilcox, AJ; Horney, LF. (1984). Accuracy of spontaneous abortion recall. Am J Epidemiol 120: 727–733. 10.1093/oxfordjournals.aje.a113940.6541871
Wild, C; Brennan, P; Plummer, M; Bray, F; Straif, K; Zavadil, J. (2015). Cancer risk: Role of chance overstated [Letter]. Science 347: 728–728. 10.1126/science.aaa6799.
Williams, HC; Burney, PG; Pembroke, AC; Hay, RJ. (1996). Validation of the U.K. diagnostic criteria for atopic dermatitis in a population setting. Br J Dermatol 135: 12–17. 10.1046/j.1365-2133.1996.d01-925.x.8776351
Wilmer, JWG, M; Woutersen, RA; Appelman, LM; Leeman, WR; Feron, VJ. (1987). Subacute (4-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8-hour continuous exposures. J Appl Toxicol 7: 15–16. 10.1002/jat.2550070104.3611592
Wilmer, JWG, M; Woutersen, RA; Appelman, LM; Leeman, WR; Feron, VJ. (1989). Subchronic (13-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8hour continuous exposures. Toxicol Lett 47: 287–293. 10.1016/0378-4274(89)90147-1.2749773
Wilson, A; Laurenti, E; Trumpp, A. (2009). Balancing dormant and self-renewing hematopoietic stem cells [Review]. 19: 461–468. 10.1016/j.gde.2009.08.005.
Wisniewski, JR; Zougman, A; Mann, M. (2008). N-epsilon-Formylation of lysine is a widespread post-translational modification of nuclear proteins occurring at residues involved in regulation of chromatin function. Nucleic Acids Res 36: 570–577. 10.1093/nar/gkm1057.18056081
Witek, TJ, Jr; Schachter, EN; Tosun, T; Beck, GJ; Leaderer, BP. (1987). An evaluation of respiratory effects following exposure to 2.0 ppm formaldehyde in asthmatics: Lung function, symptoms, and airway reactivity. Arch Environ Health 42: 230–237.3310924
Witek, TJ, Jr; Schachter, EN; Tosun, T; Leaderer, BP; Beck, GJ. (1986). Controlled human studies on the pulmonary effects of indoor air pollution: Experiences with sulfur dioxide and formaldehyde. Environ Int 12: 129–135. 10.1016/0160-4120(86)90023-1.
Wodarz, D; Zauber, AG. (2015). Cancer: Risk factors and random chances [Comment]. Nature 517: 563–564. 10.1038/517563a.25631443
Wolf, DC; Gross, EA; Lyght, O; Bermudez, E; Recio, L; Morgan, KT. (1995a). Immunohistochemical localization of p53, PCNA, and TGF-alpha proteins in formaldehyde-induced rat nasal squamous cell carcinomas. Toxicol Appl Pharmacol 132: 27–35. 10.1006/taap.1995.1083.7747282
Wolf, DC; Morgan, KT; Gross, EA; Barrow, C; Moss, OR; James, RA; Popp, JA. (1995b). 2-YEAR INHALATION EXPOSURE OF FEMALE AND MALE B6C3F1 MICE AND F344 RATS TO CHLORINE GAS INDUCES LESIONS CONFINED TO THE NOSE. Fundam Appl Toxicol 24: 111–131.7713334
Wong, V; Cash, HL; Morse, JL; Lu, S; Zhitkovich, A. (2012). S-phase sensing of DNA-protein crosslinks triggers TopBP1-independent ATR activation and p53-mediated cell death by formaldehyde. Cell Cycle 11: 2526–2537. 10.4161/cc.20905.22722496
Woolf, CJ; Salter, MW. (2000). Neuronal plasticity: increasing the gain in pain [Review]. Science 288: 1765–1769. 10.1126/science.288.5472.1765.10846153
Wortley, P; Vaughan, TL; Davis, S; Morgan, MS; Thomas, DB. (1992). A case-control study of occupational risk factors for laryngeal cancer. Br J Ind Med 49: 837–844. 10.1136/oem.49.12.837.1472441
Woutersen, RA; Appelman, LM; Van Garderen-Hoetmer, A; Feron, VJ. (1986). Inhalation toxicity of acetaldehyde in rats. III. Carcinogenicity study. Toxicology 41: 213–231. 10.1016/0300-483X(86)90201-5.3764943
Woutersen, RA; Appelman, LM; Wilmer, JWG, M; Falke, HE; Feron, VJ. (1987). Subchronic (13-week) inhalation toxicity study of formaldehyde in rats. J Appl Toxicol 7: 43–49. 10.1002/jat.2550070108.3611596
Woutersen, RA; van Garderen-Hoetmer, A; Bruijntjes, JP; Zwart, A; Feron, VJ. (1989). Nasal tumours in rats after severe injury to the nasal mucosa and prolonged exposure to 10 ppm formaldehyde. J Appl Toxicol 9: 39–46. 10.1002/jat.2550090108.2926095
Wu, H; Romieu, I; Seinra-Monge, J; del Rio-Navarro, BE; Anderson, DM; Jenchura, CA; Li, H; Ramirez-Aguilar, M; Lara-Sanchez, I; London, SJ. (2007). Genetic variation in S-nitrosoglutathione reductase (GSNOR) and childhood asthma. J Allergy Clin Immunol 120: 322–328. 10.1016/j.jaci.2007.04.022.17543375
Wu, Y; You, H; Ma, P; Li, L; Yuan, Y; Li, J; Liu, X; Yao, H; Chen, R; Lai, K; Yang, X. (2013). Role of transient receptor potential ion channels and evoked levels of neuropeptides in a formaldehyde-induced model of asthma in Balb/c mice. PLoS ONE 8: e62827. 10.1371/journal.pone.0062827.23671638
Xing Sy, L Y. (2007). Toxic effect of formaldehyde on reproduction and heredity in male mice. Journal of Jilin University - Medicine Edition 33.
Xing, SY; Ye, L; Wang, NN. (2007a). Toxic effect of formaldehyde on reproduction and heredity in male mice. Journal of Jilin University - Medicine Edition 33: 716–718.
Xing, SY; Ye, L; Wang, NN. (2007b). [Toxic effect of formaldehyde on reproduction and heredity in male mice]. Journal of Jilin University - Medicine Edition 33: 716–718.
Xiong, GX; Zhan, JM; Jiang, HY; Li, JF; Rong, LW; Xu, G. (2008). Computational fluid dynamics simulation of airflow in the normal nasal cavity and paranasal sinuses [Case Report]. Am J Rhinol 22: 477–482. 10.2500/ajr.2008.22.3211.18954506
Yamamoto, Y; Shioda, N; Han, F; Moriguchi, S; Fukunaga, K. (2010a). [Donepezil-induced neuroprotection of acetylcholinergic neurons in olfactory bulbectomized mice] [Review]. Yakugaku Zasshi 130: 717–721.20460870
Yamamoto, Y; Uchima, T; Konoike, Y; Nakamine, H. (2010b). Myeloid sarcoma in the nasal cavities that developed during the course of acute myelomonocytic leukemia [Letter]. J Clin Exp Hematop 50: 167–170. 10.3960/jslrt.50.167.21123976
Yan, Y; Ye, Z; Lu, ZS; Qiao, Y; Yang, X; Li, CM. (2005). Nitric oxide level associated with gaseous formaldehyde exposure in lungs of mice. In X Yang; B Zhao; R Zhao (Eds.), Indoor Air 2005: Proceedings of the 10th International Conference on Indoor Air Quality and Climate, vol 5 (pp. 3851–3854). Beijing, China: Tsinghua University Press. https://www.isiaq.org/docs/PDFs/3851.pdf.
Yang, W; Su, Z; Xu, Z; Yang, W; Peng, Y, ue; Li, J. (2020). Comparative study of alpha-, beta-, gamma- and delta-MnO2 on toluene oxidation: Oxygen vacancies and reaction intermediates. Appl Catal B-Environ 260. 10.1016/j.apcatb.2019.118150.
Yang, WH. (2007). [Hemogram of workers exposed to low concentration of formaldehyde] (pp. 792–799). Yang, WH.
Yang, X; Zhang, YP; Chen, D; Chen, WG; Wang, R. (2001). Eye irritation caused by formaldehyde as an indoor air pollution--a controlled human exposure experiment. Biomed Environ Sci 14: 229–236.11723723
Yang, XR; Diehl, S; Pfeiffer, R; Chen, CJ; Hsu, WL; Dosemeci, M; Cheng, YJ; Sun, B; Goldstein, AM; Hildesheim, A; Team, CaAGEoNS. (2005). Evaluation of risk factors for nasopharyngeal carcinoma in high-risk nasopharyngeal carcinoma families in Taiwan. Cancer Epidemiol Biomarkers Prev 14: 900–905. 10.1158/1055-9965.EPI-04-0680.15826929
Ye, X; Ji, Z; Wei, C; Mchale, C; Ding, S; Thomas, R; Yang, X; Zhang, L. (2013a). Inhaled formaldehyde induces DNA-protein crosslinks and oxidative stress in the bone marrow and other distant organs of exposed mice [Abstract]. Environ Mol Mutagen 54: S41.
Ye, X; Ji, Z; Wei, C; Mchale, CM; Ding, S; Thomas, R; Yang, X; Zhang, L. (2013b). Inhaled formaldehyde induces DNA-protein crosslinks and oxidative stress in bone marrow and other distant organs of exposed mice. Environ Mol Mutagen 54: 705–718. 10.1002/em.21821.24136419
Ye, X; Yan, W; Xie, H; Zhao, M; Ying, C. (2005). Cytogenetic analysis of nasal mucosa cells and lymphocytes from high-level long-term formaldehyde exposed workers and low-level short-term exposed waiters. Mutat Res 588: 22–27. 10.1016/j.mrgentox.2005.08.005.16257574
Yeatts, KB; El-Sadig, M; Leith, D; Kalsbeek, W; Al-Maskari, F; Couper, D; Funk, WE; Zoubeidi, T; Chan, RL; Trent, CB; Davidson, CA; Boundy, MG; Kassab, MM; Hasan, MY; Rusyn, I; Gibson, JM; Olshan, AF. (2012). Indoor air pollutants and health in the United Arab Emirates. Environ Health Perspect 120: 687–694. 10.1289/ehp.1104090.22357138
Yendamuri, S; Calin, GA. (2009). The role of microRNA in human leukemia: A review [Review]. Leukemia 23: 1257–1263. 10.1038/leu.2008.382.19148134
Ying, CJ; Yan, WS; Zhao, MY; Ye, XL; Xie, H; Yin, SY; Zhu, XS. (1997). Micronuclei in nasal mucosa, oral mucosa and lymphocytes in students exposed to formaldehyde vapor in anatomy class. Biomed Environ Sci 10: 451–455.9448927
Ying, CJ; Ye, XL; Xie, H; Yan, WS; Zhao, MY; Xia, T; Yin, SY. (1999). Lymphocyte subsets and sister-chromatid exchanges in the students exposed to formaldehyde vapor. Biomed Environ Sci 12: 88–94.10560533
Yon, DK; Hwang, S; Lee, SW; Jee, HM; Sheen, YH; Kim, JH; Lim, DH; Han, MY. (2019). Indoor Exposure and Sensitization to Formaldehyde among Inner-City Children with Increased Risk for Asthma and Rhinitis. Am J Respir Crit Care Med 200: 388–393. 10.1164/rccm.201810-1980LE.30958969
Yonemitsu, T; Kuroki, C; Takahashi, N; Mori, Y; Kanmura, Y; Kashiwadani, H; Ootsuka, Y; Kuwaki, T. (2013). TRPA1 detects environmental chemicals and induces avoidance behavior and arousal from sleep. Sci Rep 3: 3100. 10.1038/srep03100.24172941
Yorgancilar, E; Deveci, E; Deveci, S. (2012). Effects of formaldehyde on respiratory mucosa in rats. International Journal of Morphology 30: 521–523. 10.4067/S0717-95022012000200026.
Yoshida, I; Ibuki, Y. (2014). Formaldehyde-induced histone H3 phosphorylation via JNK and the expression of proto-oncogenes. Mutat Res 770: 9–18. 10.1016/j.mrfmmm.2014.09.003.25771866
Young, JT. (1981). Histopathologic examination of the rat nasal cavity. Fundam Appl Toxicol 1: 309–312. 10.1016/S0272-0590(81)80037-1.6764423
Young, RP; Hopkins, R; Eaton, TE. (2007). Forced expiratory volume in one second: not just a lung function test but a marker of premature death from all causes [Review]. Eur Respir J 30: 616–622. 10.1183/09031936.00021707.17906084
Yu, GY; Song, XF; Liu, Y; Sun, ZW. (2014). Inhaled Formaldehyde Induces Bone Marrow Toxicity via Oxidative Stress in Exposed Mice. Asian Pac J Cancer Prev 15: 5253–5257. 10.7314/APJCP.2014.15.13.5253.25040984
Yu, IT; Li, AM; Goggins, W; Leung, JO; Chan, GY; Fung, CK; Chan, CK; Lau, AP. (2017). Association of wheeze during the first 18 months of life with indoor nitrogen dioxide, formaldehyde, and family history of asthma: a prospective cohort study. Hong Kong Med J 23 Suppl 2: 19–23.
Yu, ITS; Chin, YL; Wong, TW; Tang, JL. (2004). Deaths from nasopharyngeal cancer among waiters and waitresses in Chinese restaurants. Int Arch Occup Environ Health 77: 499–504. 10.1007/s00420-004-0543-0.15558301
Yu, MC; Lai, SH; Henderson, BE. (1986). Cantonese-style salted fish as a cause of nasopharyngeal carcinoma: Report of a case-control study in Hong Kong. Cancer Res 42: 956–961.
Yu, R; Lai, Y; Hartwell, HJ; Moeller, BC; Doyle-Eisele, M; Kracko, D; Bodnar, WM; Starr, TB; Swenberg, JA. (2015a). Formation, Accumulation, and Hydrolysis of Endogenous and Exogenous Formaldehyde-Induced DNA Damage. Toxicol Sci 146: 170–182. 10.1093/toxsci/kfv079.25904104
Yu, R; Lai, Y; Hartwell, HJ; Moeller, BC; Doyle-Eisele, M; Kracko, D; Bodnar, WM; Starr, TB; Swenberg, JA. (2015b). Formation, Accumulation, and Hydrolysis of Endogenous and Exogenous Formaldehyde-Induced DNA Damage - supplemental data [Supplemental Data]. Toxicol Sci 146.
Yu, YH; Blessing, WW. (1997). Cerebral blood flow in rabbits during the nasopharyngeal reflex elicited by inhalation of noxious vapor. J Auton Nerv Syst 66: 149–153. 10.1016/s0165-1838(97)00080-5.9406119
Yu, YH; Blessing, WW. (1999). Amygdala co-ordinates sudden falls in ear pinna blood flow in response to unconditioned salient stimuli in conscious rabbits. Neuroscience 93: 135–141. 10.1016/s0306-4522(99)00097-4.10430478
Zeller, J; Neuss, S; Mueller, JU; Kühner, S; Holzmann, K; Högel, J; Klingmann, C; Bruckner, T; Triebig, G; Speit, G. (2011). Assessment of genotoxic effects and changes in gene expression in humans exposed to formaldehyde by inhalation under controlled conditions. Mutagenesis 26: 555–561. 10.1093/mutage/ger016.21460374
Zendehdel, R; Jouni, FJ; Hajipour, B; Panjali, Z; Kheiri, H; Vahabi, M. (2017). DNA damage in workers exposed to formaldehyde at concentrations below occupational exposure limits. Toxicol Environ Chem 99: 1409–1417. 10.1080/02772248.2017.1343335.
Zhai, L; Zhao, J; Xu, B; Deng, Y; Xu, Z. (2013). Influence of indoor formaldehyde pollution on respiratory system health in the urban area of Shenyang, China. Afr Health Sci 13: 137–143. 10.4314/ahs.v13i1.19.23658580
Zhang, B; Shi, Y; Chen, X, in; Dai, J; Jiang, ZF, a; Li, N; Zhang, Z. (2013a). Protective effect of curcumin against formaldehyde-induced genotoxicity in A549 Cell Lines. J Appl Toxicol 33: 1468–1473. 10.1002/jat.2814.23059809
Zhang, L; Lan, Q; Guo, W; Hubbard, AE; Li, G; Rappaport, SM; Mchale, CM; Shen, M; Ji, Z; Vermeulen, R; Yin, S; Rothman, N; Smith, MT. (2011). Chromosome-wide aneuploidy study (CWAS) in workers exposed to an established leukemogen, benzene. Carcinogenesis 32: 605–612. 10.1093/carcin/bgq286.21216845
Zhang, L; Steinmaus, C; Eastmond, DA; Xin, XK; Smith, MT. (2009). Formaldehyde exposure and leukemia: A new meta-analysis and potential mechanisms [Review]. Mutat Res Rev Mutat Res 681: 150–168. 10.1016/j.mrrev.2008.07.002.
Zhang, L; Tang, X; Rothman, N; Vermeulen, R; Ji, Z; Shen, M; Qiu, C; Guo, W; Liu, S; Reiss, B; Freeman, LB; Ge, Y; Hubbard, AE; Hua, M; Blair, A; Galvan, N; Ruan, X; Alter, BP; Xin, KX; Li, S; Moore, LE; Kim, S; Xie, Y; Hayes, RB; Azuma, M; Hauptmann, M; Xiong, J; Stewart, P; Li, L; Rappaport, SM; Huang, H; Fraumeni, JF, Jr; Smith, MT; Lan, Q. (2010). Occupational exposure to formaldehyde, hematotoxicity, and leukemia-specific chromosome changes in cultured myeloid progenitor cells. Cancer Epidemiol Biomarkers Prev 19: 80–88. 10.1158/1055-9965.EPI-09-0762.20056626
Zhang, Q; Yan, W; Bai, Y; Zhu, Y; Ma, J. (2014). Repeated formaldehyde inhalation impaired olfactory function and changed SNAP25 proteins in olfactory bulb. Int J Occup Environ Health 20: 308–312. 10.1179/2049396714Y.0000000079.25131264
Zhang, Y; Liu, X; Mchale, C; Li, R; Zhang, L; Wu, Y; Ye, X; Yang, X; Ding, S. (2013b). Bone marrow injury induced via oxidative stress in mice by inhalation exposure to formaldehyde. PLoS ONE 8: e74974. 10.1371/journal.pone.0074974.24040369
Zhao, B; Nakada, N; Itai, S; Hanamoto, S; Okumura, K; Tanaka, H. (2020a). Diurnal patterns of N-nitrosodimethylamine and formaldehyde behaviors in different seasons in surface water influenced by effluent from sewage treatment plants. J Hazard Mater 383: 121155. 10.1016/j.jhazmat.2019.121155.31639613
Zhao, Y, un; Magana, LC; Cui, H; Huang, J; Mchale, CM; Yang, X, u; Looney, MR; Li, R, ui; Zhang, L. (2020b). Formaldehyde-induced hematopoietic stem and progenitor cell toxicity in mouse lung and nose. Arch Toxicol 95: 693–701. 10.1007/s00204-020-02932-x.33084937
Zheng, W; Blot, WJ; Shu, XO; Diamond, EL; Gao, YT; Ji, BT; Fraumeni, J. R. (1992). A population-based case-control study of cancers of the nasal cavity and paranasal sinuses in Shanghai. Int J Cancer 52: 557–561. 10.1002/ijc.2910520410.1399136
Zhong, W; Hee, SQ. (2004). Quantitation of normal and formaldehyde-modified deoxynucleosides by high-performance liquid chromatography/UV detection. Biomed Chromatogr 18: 462–469. 10.1002/bmc.337.15340972
Zhou, D; Zhang, J; Wang, H. (2011a). Assessment of the potential reproductive toxicity of long-term exposure of adult male rats to low-dose formaldehyde. Toxicol Ind Health 27: 591–598. 10.1177/0748233710393401.21357637
Zhou, D; Zhang, J; Wang, H; Xue, Y. (2011b). Effect of formaldehyde exposure on structure and function of epididymis in adult rats: A histological and biochemical study. Toxicol Environ Chem 93: 134–144. 10.1080/02772248.2010.501145.
Zhou, DX; Qiu, SD; Zhang, J; Tian, H; Wang, HX. (2006). The protective effect of vitamin E against oxidative damage caused by formaldehyde in the testes of adult rats. Asian J Androl 8: 584–588. 10.1111/j.1745-7262.2006.00198.x.16751993
Zhou, ES; Kane, YY; Gao, XX; Wu, LF; Lu, ZS; Yan, Y; Qiao, Y; Yang, X. (2005). A pilot investigation on human serum formaldehyde-specific IgE. Paper presented at 10th International Conference on Indoor Air Quality and Climate, September 4-9, 2005, Beijing, China.
Zhu, JL; Knudsen, LE; Andersen, AM; Hjollund, NH; Olsen, J. (2005). Time to pregnancy among Danish laboratory technicians who were a part of the National Birth Cohort. Scand J Work Environ Health 31: 108–114.15864904
Zhu, JL; Knudsen, LE; Andersen, AM; Hjollund, NH; Olsen, J. (2006). Laboratory work and pregnancy outcomes: a study within the National Birth Cohort in Denmark. Occup Environ Med 63: 53–58. 10.1136/oem.2005.021204.16361406
Zwart, A; Woutersen, RA; Wilmer, JWG, M; Spit, BJ; Feron, VJ. (1988). Cytotoxic and adaptive effects in rat nasal epithelium after 3-day and 13-week exposure to low concentrations of formaldehyde vapour. Toxicology 51: 87–99. 10.1016/0300-483X(88)90083-2.3413803