# AUTHORS | CONTRIBUTORS | REVIEWERS

Assessment Managers (Lead Authors)
Andrew Kraft (https://orcid.org/0000-0003-3630-6741), Ph.D. (Assessment Comanager: 2011-Present) | EPA/ORD/CPHEA
Thomas F. Bateson (https://orcid.org/0000-0003-1355-5745), Sc.D. (Assessment Comanager: 2022-Present)
Barbara Glenn, Ph.D. (Assessment Comanager: 2011-2022; retired)
Authors
Glinda Cooper, Ph.D. (retired) | EPA/ORD/CPHEA
Jennifer Jinot, Ph.D. (retired)
Sue Makris, M.S. (retired)
Deborah Segal (https://orcid.org/0000-0002-0591-0295), M.S.
Ravi Subramaniam (https://orcid.org/0000-0001-5588-4120), Ph.D.
Suryanarayana Vulimiri (https://orcid.org/0000-0003-3734-0036), Ph.D.
John Whalan, B.S. (retired)
Jason Fritz, Ph.D. | EPA/Region 8
Contributors
Lynn Adams, Ph.D. (separated from EPA) | EPA/ORD/CPHEA
Michelle Angrish (https://orcid.org/0000-0002-4956-4806), Ph.D.
David Bayliss, M.S. (retired)
Jane Caldwell, Ph.D. (retired)
Danielle DeVoney, Ph.D. (retired)
Jeff Gift, Ph.D.
Karen Hogan, M.S. (retired)
Jacqueline Moya, M.S. (retired)
Brian Pachkowski, Ph.D. (separated from EPA)
Amanda Persad (https://orcid.org/0000-0003-0137-1279), Ph.D.
Linda Phillips, Ph.D. (retired)
Alan Sasso, PhD. (separated from EPA)
Paul Schlosser, Ph.D.
Keith Salazar, Ph.D. | EPA/OCSPP
Executive Direction
James Avery, Ph.D. (retired) | EPA/ORD/CPHEA
Tina Bahadori, Sc.D. (separated from EPA)
David Bussard, M.S. (retired)
Wayne Cascio, M.D. (CPHEA Director)
Vincent Cogliano, Ph.D. (separated from EPA)
V. Kay Holt, M.S. (CPHEA Deputy Director)
Lynn Flowers, Ph.D. (retired)
Samantha Jones, Ph.D. (CPHEA Associate Director)
Emma Lavoie, Ph.D. (former Associate Director)
Babashaheb (Bob) Sonawane, PhD. (retired)
Kristina Thayer, Ph.D. (CPAD Director)
Paul White, Ph.D. (CPAD Science Advisor)
Production Team
Michaela Burns (Communications Team) | EPA/ORD/CPHEA
Brooke Holmes (Project Management Team)
Antoinette Johnson (Project Management Team)
Maureen Johnson (Webmaster)
Ryan Jones (HERO Director)
Jack Rehmann (CPHEA Webmaster)
Dahnish Shams (Project Management Team)
Avanti Shirke (Project Management Team)
Emily Snyder (Communications Director)
Vicki Soto (Branch Chief; Project Management Lead)
Jessica Soto-Hernandez (Project Management Team)
Samuel Thacker (HERO Team)
Garland Waleko (Project Management Team)

## Reviewers

This assessment was provided for review to scientists in EPA’s program and regional offices. Comments were submitted by:

- Office of the Administrator/Office of Children’s Health Protection (Step 2)
- Office of Air and Radiation (Step 2)
- Office of Chemical Safety and Pollution Prevention (Step 2 and Step 6)
- Office of Land and Emergency Management (Step 2)
- Region 2, New York City, NY (Step 2)
- Region 4, Atlanta, GA (Step 2)
- Region 8, Denver, CO (Step 6)

This assessment was provided for review to other federal agencies and the Executive Office of the President (EOP). Comments were submitted by:

- The White House
  - Office of Management and Budget (Step 3 (https://iris.epa.gov/document/%26deid=353316))
- Department of Agriculture (Step 6 (https://iris.epa.gov/document/%26deid=356871))
- Department of Defense (Step 3 (https://iris.epa.gov/document/%26deid=353316))
- Small Business Administration (Step 3 (https://iris.epa.gov/document/%26deid=353316))
- Department of Health and Human Services
  - National Institute of Environmental Health Sciences (Step 3 (https://iris.epa.gov/document/%26deid=353316))
  - Agency for Toxic Substances and Disease Registry (Step 3 (https://iris.epa.gov/document/%26deid=353316) and Step 6 (https://iris.epa.gov/document/%26deid=356871))
  - National Institute of Occupational Safety and Health (Step 3 (https://iris.epa.gov/document/%26deid=353316) and Step 6 (https://iris.epa.gov/document/%26deid=356871))

This assessment was released for public comment on April 14, 2022, and comments were due on June 13, 2022. The public comments are available on Regulations.gov [docket: EPA-HQ-ORD-2010-0396]. A summary and EPA’s disposition of the comments from the public is available in Appendix F.

This assessment was peer reviewed by independent, expert scientists external to EPA convened by the National Academies of Sciences, Engineering, and Medicine (NASEM). Peer-review meetings were held by NASEM (https://www.nationalacademies.org/our-work/review-of-epas-2022-draft-formaldehyde-assessment). The report of the review of the EPA’s Draft Toxicological Review of Formaldehyde (Inhalation), dated 2023, is available on the NASEM website (https://nap.nationalacademies.org/catalog/27153/review-of-epas-2022-draft-formaldehyde-assessment) and the IRIS Website (https://iris.epa.gov/Document/&deid=248150). A summary and EPA’s disposition of the comments received is included in Appendix F.