# 5 DERIVATION OF TOXICITY VALUES

## 5.1 INHALATION REFERENCE CONCENTRATION FOR EFFECTS OTHER THAN CANCER

This section describes analyses that better characterize the “sufficient exposure conditions” necessary for formaldehyde inhalation exposure to cause the identified noncancer human health hazards (see Sections 3.2.1 to 3.2.4 and 3.3.1 to 3.3.2, as summarized in Section 4.2), culminating in selection of a reference concentration (RfC). The RfC (expressed in units of mg/m^3^) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a no-observed-adverse-effect level (NOAEL), lowest-observed-adverse-effect level (LOAEL), or the 95% (typically) lower bound on the benchmark concentration (BMCL), with uncertainty factors (UFs) generally applied to reflect limitations of the data used. The approach for deriving an overall RfC involves the following steps, specific methods and considerations which are outlined within each of the subsequent sections:

1) Identify studies and endpoints for each health effect that are sufficient (i.e., with one of the two strongest evidence integration judgments for hazard, namely of evidence demonstrates or evidence indicates, and high or medium confidence in the study methods and results, as well as data considered to be most amenable for dose-response analysis to represent the identified hazards)
2) Calculate points of departure (PODs) from the studies
3) Derive candidate RfCs (cRfCs) by applying UFs to the PODs
4) Select organ- or system-specific RfCs (osRfCs) based on the cRfCs
5) Select an overall RfC based on the osRfCs

Candidate RfCs (cRfCs) were derived from studies supporting several health hazards, including sensory irritation (eye irritation symptoms), pulmonary function (peak expiratory flow rate), allergies (rhinoconjunctivitis, atopic eczema), current asthma (i.e., symptoms or medication in the previous 12 months), degree of asthma control, respiratory tract pathology (squamous metaplasia), developmental toxicity (delayed time to pregnancy), and male reproductive toxicity (testes weight, serum testosterone). Based on the hazard synthesis conclusions (see Section 3), for many health effects, specific endpoints were prioritized for use in dose-response evaluation (e.g., squamous metaplasia rather than hyperplasia for respiratory tract pathology). The cRfCs for sensory irritation, pulmonary function, immune effects including allergies and current asthma, and female and developmental toxicity were derived using data from human epidemiology and controlled exposure studies, while the cRfCs for respiratory tract pathology and male reproductive toxicity were derived using data from experimental animals. cRfCs were not derived for nervous system effects, as the available evidence was deemed to be too uncertain, and thus insufficient, to support quantitative dose-response assessment. In this case, the primary sources of uncertainty in the data included study-specific methodological limitations^41^ and a lack of reproducibility across well-conducted studies within the databases for the individual outcomes evaluated.

As documented in Section 5.1.1, the studies considered to be most applicable to formaldehyde exposure settings in the general population were preferred for use in dose-response analyses. The strengths and limitations of the available studies (i.e., for use in dose-response, as documented in Section 5.1.1) were considered alongside uncertainties in deriving PODs for the studies which were advanced (see Section 5.1.2) to determine a level of confidence in each derived cRfC (Section 5.1.3). This level of confidence in the cRfCs was incorporated into the derivation of the organ- or system- specific RfCs (osRfCs; see Section 5.1.4). An overall RfC for formaldehyde of 0.007 mg/m^3^ was selected. This value is the midpoint of the three osRfCs with the highest confidence and least uncertainty (0.006, 0.007, and 0.008 mg/m^3^) representing a group of respiratory system-related hazards (i.e., pulmonary function, allergy-related conditions, and current asthma prevalence or degree of control). The RfC is interpreted with high confidence. Uncertainties in the RfC are discussed with the rationale for the RfC selection in Section 5.1.5.

While the RfC is interpreted to be a concentration associated with negligible risk over a lifetime of exposure, a few of the hazards or outcomes for which cRfCs are derived, including sensory irritation symptoms and the degree of asthma control, could be relevant to a shorter exposure time-frame. The applicability of such cRfCs to shorter exposure periods is noted for the relevant hazards.

### 5.1.1 Choice of Studies

Data sufficient to support dose-response analyses were available for all of the health systems for which the integration of all the evidence resulted in judgments of evidence demonstrates or evidence indicates that inhalation of formaldehyde can cause adverse human health effects. Rationales for study selection are detailed in this section using tables within each health effect-specific section that apply the criteria from Section 2.7 to the available high or medium confidence studies to identify those amenable to dose-response analysis and select those most appropriate for use in POD derivation (Section 5.1.2), with an explanatory rationale.

#### Methods of Analysis

From among the body of evidence used for the hazard identification assessment, selection of the studies for dose-response assessment used information from the study confidence evaluations, with particular emphasis on conclusions regarding the characteristics of the study population and the accuracy of formaldehyde exposure, the severity of the observed effects, and the exposure levels analyzed. Section 2.7 outlines the specific considerations for selecting studies for dose-response analysis. The application of these considerations and the rationale for selecting specific studies over others is outlined in tables within each health effect-specific section below. Generally, human studies were preferred over laboratory animal studies if quantitative measures of exposure were analyzed in relation to health endpoints. Epidemiological studies that evaluated groups most representative of the general population (i.e., residential or school-based study populations) were preferred if exposure-response analyses were presented. These criteria emphasize the use of high or medium confidence studies with appropriate study designs, complete reporting of results, and results that would not be reasonably explained by selection bias or information bias or altered by adjustment for confounding. Studies with risk estimates for multiple exposure levels or regression coefficients per unit of formaldehyde concentration were preferred because they provided information about the concentration-response trend. The presence of an exposure-response gradient and analyses of data at lower exposure levels were considered.

If there were no adequate studies of human exposure for exposure-response analysis, then studies of experimental animals were evaluated. Using similar criteria as described for human studies (above), the overall quality of the experimental animal studies was considered (e.g., preference was given to studies with less likelihood of bias, confounding, etc.). As described in Section 2.7 and as documented in each health effect-specific section below, experimental animal studies were generally preferred if they were from models that respond most like humans; tested the effects of formaldehyde inhalation exposure using paraformaldehyde as the test article; were of longer exposure duration and follow-up, evaluated across multiple exposure levels; and were adequately powered to detect effects at lower exposure levels.

#### Sensory Irritation

The effects of formaldehyde on sensory irritation are understood to occur as a result of direct interactions of formaldehyde with cellular macromolecules leading directly or indirectly to stimulation of trigeminal nerve endings; branches of the trigeminal nerve responsible for chemosensation innervate the oral, ocular, and nasal cavities. However, the most notable and well-studied of these is activation within the nasal mucosa (i.e., in the respiratory epithelium) and stimulation in the oral cavity is unlikely to lead to eye irritation or similar symptoms. Such stimulation results in the rapid detection of a burning sensation (see Section 3.2.1). It is not clear if desensitization occurs over time or the concentrations or timeframes over which this might occur. Because of the rapid nature of the irritant response generated by inhalation of formaldehyde, the studies that were considered to be the most informative for derivation of a cRfC were those where the exposure assessment was concurrent with the outcome assessment.

Data from studies in humans involving residential populations with continuous exposure, as well as controlled human exposure studies evaluating acute effects were determined to be pertinent to the derivation of cRfCs. The studies of anatomy students and formaldehyde-exposed workers assessed exposure settings with high formaldehyde concentrations and with frequent peaks. Thus, average formaldehyde concentrations or TWAs, the exposure metrics used by these studies, could not capture the variation inherent in these types of settings. Therefore, the large uncertainty in deriving a POD based on results of studies in these high and variable exposure settings was considered to have been a critical concern and PODs were not derived for these exposure scenarios. After evaluating the available medium and high confidence studies on sensory irritation for their utility in dose-response analysis (see Table 5-1), four studies (two controlled exposure and two epidemiology studies) were advanced for POD derivation (Liu et al., 1991; Kulle, 1993; Hanrahan et al., 1984; Andersen and Molhave, 1983).

Table 5-1 Studies selected for POD derivation and rationale for decisions to not select specific studies for sensory irritation

Study, endpoint | Dose-response considerations (see methods in Section 2.7) | | | | | Decision
Study, endpoint | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Residential Studies
(Zhai et al., 2013); Nose and throat irritation | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Potential information bias (exposure sampling time-frame) | N/A | Critical concern:; [--] Analyses of formaldehyde using a dichotomous variable | No POD derived. Critical concern with results utility for POD derivation.
(Liu et al., 1991), Eye irritation prevalence | [n] Medium confidence; [+] Information bias unlikely; [n] Selection bias possible due to low participation rate, but unlikely due to formaldehyde exposure; [+] Confounding unlikely | [+] Diverse population | [+] 7-d passive sampling; [n] 2 area samples per home; [+] Continuous exposure; [+] Wide exposure range; [+] Lowest indoor exposure level = 0.01 ppm | [n] Self-report; [n] Survey not described; [+] symptoms were reported for the week during the monitoring period | [+] N = 836 homes; [n] Logistic regression (dose-response data can be estimated from results presented graphically) | POD estimated in combination with (Hanrahan et al., 1984), limitations noted.
(Liu et al., 1991), Eye irritation prevalence | [n] Medium confidence; [+] Information bias unlikely; [n] Selection bias possible due to low participation rate, but unlikely due to formaldehyde exposure; [+] Confounding unlikely | [+] Diverse population | [+] 7-d passive sampling; [n] 2 area samples per home; [+] Continuous exposure; [+] Wide exposure range; [+] Lowest indoor exposure level = 0.01 ppm | [n] Self-report; [n] Survey not described; [+] symptoms were reported for the week during the monitoring period | Some concern:; [-] Model parameters not reported | POD estimated in combination with (Hanrahan et al., 1984), limitations noted.
(Hanrahan et al., 1984), Eye irritation prevalence | [n] Medium confidence; [+] Selection bias and confounding unlikely | [+] Diverse population; (including teens) | [+] Method matched NIOSH 3500^f^ including sampling time of 1 hr; [n] 2 area samples per home; [+] Continuous exposure; [+] QC showed no issues; [+] Wide exposure range; [n] Lowest indoor exposure level = 0.1 ppm | [n] Self-report; [n] Survey not described | [n] N = 61; [n] Logistic regression (dose-response data can be estimated from results presented graphically) | POD estimated in combination with (Liu et al., 1991), limitations noted.
(Hanrahan et al., 1984), Eye irritation prevalence | [n] Medium confidence; [+] Selection bias and confounding unlikely | [+] Diverse population; (including teens) | Some concern:; [-] Potential information bias (exposure sampling time-frame) | Some concern:; [-] Symptoms recalled for any time in residence: sampling time-frame does not match outcome ascertainment time-frame | Some concern:; [-] Model parameters not reported | POD estimated in combination with (Liu et al., 1991), limitations noted.
(Olsen and Dossing, 1982) Eye, nose, and throat irritation | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Potential information bias (exposure sampling time-frame) | N/A | Critical concern:; [--] Compared symptoms in exposed to referent group | No POD derived. Critical concern with results utility for POD derivation
Controlled Exposure Studies
(Mueller et al., 2013)^b^, Eye irritation scaled score, nasal flow, blinking frequency, conjunctival redness, tear film break-up time | [+] High confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers only | [n] Acute exposure appropriate for endpoint; [+] Lowest indoor exposure level = 0.01 ppm | [+] Self-report plus objective measures | [n] N = 41 | No POD derived. Data less sensitive or not dose-dependent, in addition to some concerns with the population and outcome measures. No dose-response trend was observed and difficult to determine adversity cutoff. Less preferred exposure metric. Studies with more robust analyses available.
(Mueller et al., 2013)^b^, Eye irritation scaled score, nasal flow, blinking frequency, conjunctival redness, tear film break-up time | [+] High confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers only | Some concern:; [-] Exposure protocol less relevant to RfC derivation (included peak concentrations over a continuous background) | [+] Self-report plus objective measures | Some concern:; [-] Within person comparisons with correlated responses across dose levels; [-] Dose-response trend not observed; [-] Several effects null or not significant
(Mueller et al., 2013)^b^, Eye irritation scaled score, nasal flow, blinking frequency, conjunctival redness, tear film break-up time | [+] High confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers only | Some concern:; [-] Exposure protocol less relevant to RfC derivation (included peak concentrations over a continuous background) | Some concern:; [-] Large interindividual variability and difficult to determine adversity cutoff | Some concern:; [-] Within person comparisons with correlated responses across dose levels; [-] Dose-response trend not observed; [-] Several effects null or not significant
Berglund et al. (2012), detection of odor and nasal irritation | [+] Medium confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers | [n] Acute exposure appropriate for endpoint | Some concern:; [-] Large interindividual variability in detections at same concentration.; [-] Difficult to interpret the measure (% of presentations with correct detection) to define adversity cutoff. | [n] N = 31 | No POD derived. Difficult to interpret the measure used, in addition to some concerns with the population and outcome measures. Studies with more robust analyses available.
Berglund et al. (2012), detection of odor and nasal irritation | [+] Medium confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers | Some concern:; [-] Exposure protocol less relevant to RfC derivation (series of 3 second sniffs) | | [n] N = 31 | No POD derived. Difficult to interpret the measure used, in addition to some concerns with the population and outcome measures. Studies with more robust analyses available.
(Lang et al., 2008)^b^, Eye irritation score, blinking frequency, conjunctival redness | [+] High confidence; [+] Selection bias and confounding unlikely; [n] Adequate exposure quality | Some concern:; [-] Healthy volunteers | [n] Acute exposure appropriate for endpoint; [n] “Quasistatic” chamber (dynamic chamber preferred) | [+] Self-report plus objective measures | [n] N = 21 | No POD derived. Data less sensitive, in addition to some concerns with the population and outcome measures. Issues with adequacy of exposure quality. Studies with more robust analyses available.
(Lang et al., 2008)^b^, Eye irritation score, blinking frequency, conjunctival redness | [+] High confidence; [+] Selection bias and confounding unlikely; [n] Adequate exposure quality | Some concern:; [-] Healthy volunteers | Some concern:; [-] Experimental issues with lingering exposures from previous day | Some concern:; [-] Difficult to determine adversity cutoff for objective measures | Some concern:; [-] Effects only at higher levels for these endpoints (note: other endpoints in this study more sensitive) | No POD derived. Data less sensitive, in addition to some concerns with the population and outcome measures. Issues with adequacy of exposure quality. Studies with more robust analyses available.
(Kulle, 1993)^b^, Eye irritation prevalence | [n] Medium confidence; [+] Selection bias and confounding unlikely; [+] Good exposure quality | Some concern:; [-] Healthy volunteers | [n] Acute exposure appropriate for endpoint | [n] Self-report symptom scores | Some concern:; [-] Irritation in controls NR; [-] Regression coefficients NR; [-] Within person comparisons with correlated responses across dose levels.; [-] Small N (N = 9-10) | POD derived, limitations noted.
(Andersen and Molhave, 1983)^b^, Eye irritation prevalence | [n] Medium confidence; [+] Selection bias and confounding unlikely; [n] Adequate exposure quality | Some concern:; [-] Healthy volunteers; [-] > 30% smokers | [n] Acute exposure appropriate for endpoint | [n] Self-report symptom scores | [n] N = 16 | POD derived, limitations noted.
(Andersen and Molhave, 1983)^b^, Eye irritation prevalence | [n] Medium confidence; [+] Selection bias and confounding unlikely; [n] Adequate exposure quality | Some concern:; [-] Healthy volunteers; [-] > 30% smokers | Some concern:; [-] Variable exposure levels, with analytical concentrations within 20% of target | [n] Self-report symptom scores | Some concern:; [-] Irritation during clean air exposure NR; [-] Within person comparisons with correlated responses across dose levels. | POD derived, limitations noted.
Other high/medium confidence studies^c^ | N/A | N/A | Critical concern:; [--] only one exposure level | N/A | N/A | No POD derived. Critical exposure concern.
Other Studies
Studies of laboratory students^d^ | N/A | N/A | Critical concern:; [--] Episodic (1–2x/ week for 1–4 hr); [--] High exposures compared to other designs | N/A | N/A | No POD derived Critical exposure concern.
Studies of workers^e^ | N/A | N/A | Critical concern:; [--] High exposures compared to other designs | N/A | N/A | No POD derived Critical exposure concern.

Representing the impact of each factor on the inferred utility of the study for dose-response analysis for this outcome: [+] = increases utility; [n] = neutral effect on utility; [-] decreases utility; [--] critical concern that greatly inhibits utility (gray shading)

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B for details).

b EPA’s Human Studies Review Board review of this intentional exposure study determined the ethical conduct to be adequate for use.

c See Appendix C.3.3. High confidence: (Green et al., 1987; Green et al., 1989); Medium confidence: (Witek et al., 1986; Witek et al., 1987; Schachter et al., 1986; Schachter et al., 1987).

d See Appendix C.4. High confidence: (Uba et al., 1989; Mori et al., 2016; Kriebel et al., 1993); Medium confidence: (Wantke et al., 2000; Takigawa et al., 2005; Takahashi et al., 2007; Kriebel et al., 2001).

e See Appendix C.4. Medium confidence: (Neghab et al., 2011; Horvath et al., 1988; Holness and Nethercott, 1989).

f “The working range is 0.02 to 4 ppm (0.025 to 4.6 mg/m^3^) for an 80-L air sample. This is the most sensitive formaldehyde method in the NIOSH Manual of Analytical Methods and is able to measure ceiling levels as low as 0.1 ppm (1 5-L sample). It is best suited for the determination of formaldehyde in area samples.” (https://www.cdc.gov/niosh/docs/2003-154/chaps.html); NIOSH Manual of Analytical Methods, 4th Edition (NMAM 3500) (NIOSH, 1994).

#### Pulmonary Function

As described in Section 3.2.2, the synthesis judgments were based on human studies of long-term formaldehyde exposure and effects on pulmonary function; these studies were considered in dose-response analysis. Most studies in residential settings either did not provide quantitative results needed for dose-response analysis, used dichotomized concentration data, or compared exposed groups to a referent group. The studies of effects among anatomy lab students involved episodic and high-level exposures compared to other available study designs. The occupational studies also involved high exposure levels, some with periodic peaks. Overall, after evaluating the available medium and high confidence studies on pulmonary function for their utility in dose-response analysis (see Table 5-2), one epidemiology study was advanced for POD derivation (Krzyzanowski et al., 1990).

Strengths of the Krzyzanowski et al. (1990) study include a large sample size in a residential population, with a comprehensive exposure assessment protocol (i.e., three locations in the home; two 1-week periods in each location) reasonably representing exposures in the homes during the previous weeks and months (i.e., the etiologically relevant exposure window for pulmonary function status). Additionally, the use of multiple exposures per day (morning and evening) for each child over the 12 days of exposure measurements and the twice-daily repeated measurements of PEFR enhanced the sensitivity of this study for detecting an effect on pulmonary function.

Table 5-2 Eligible studies for POD derivation and rationale for decisions to not select specific studies for pulmonary function

Study, endpoint | Dose-response considerations (see methods in Section 2.7) | | | | | Decision
Study, endpoint | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Residential Studies
(Krzyzanowski et), Peak expiratory Flow Rate (PEFR) | [+] High confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population with wide spectrum of SES, ethnicity, and ages (including children 6-15 years) | [+] Two one-week samples measured in bedroom, living area and kitchen.; [+] Continuous exposure; [+] Average exposure 26 ppb (32 μg/m^3^); [+] Wide exposure range | [+] Subjects were trained in use of the mini-Wright peak flow meter; [+] PEFR was measured for up to 4 times/day; [+] To eliminate any training effect, first 2 days measurements were excluded; [n] Self-report | [+] N = 298 children; [+] Regression parameters were provided that allowed for the dose-response to be estimated in all children and in asthmatic children | POD derived
(Wallner et al., 2012) Forced Flow volume (MEF_75_, MEF_50_) | N/A | N/A | N/A | N/A | [+] N=433; [n] Regression of % change in pulmonary function per 1 SD change in formaldehyde | No POD derived. Critical concern with results utility for POD derivation.
(Wallner et al., 2012) Forced Flow volume (MEF_75_, MEF_50_) | N/A | N/A | N/A | N/A | Critical concern: [--] Required concentration data for regression not reported. | No POD derived. Critical concern with results utility for POD derivation.
Broder et al. (1988b, 1988c); Broder et al. (1988a) Spirometry measures | N/A | N/A | N/A | N/A | Critical concern: [--] No quantitative results provided for within group regression models and formaldehyde | No POD derived. Critical concern with results utility for POD derivation.
Residential studies with analyses inadequate for dose-response^b^ | N/A | N/A | N/A | N/A | Critical concern: [--] only dichotomous analyses or comparisons of exposed to a referent group | No POD derived. Critical concern with results utility for POD derivation.
Studies of anatomy lab students^c^ | N/A | N/A | Critical concern:; [--] Episodic (1–2x/ week for 1–4 hr); [--] High exposures compared to other designs | N/A | Critical concern: [--] Analyzed changes in pulmonary function with time as the independent variable or regression parameters that complicated dose-response evaluation | No POD derived. Critical concerns with exposure and results utility for POD derivation.
Occupational exposure studies^d^ | N/A | N/A | Critical concern: [--] High exposure compared to other designs | N/A | N/A | No POD derived. Critical concern with exposure as compared to other available studies.

Representing the impact of each factor on the inferred utility of the study for dose-response analysis for this outcome: [+] = increases utility; [n] = neutral effect on utility; [-] decreases utility; [--] critical concern that greatly inhibits utility (gray shading)

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B for details).

b See Appendix B.3.3. Medium (Franklin et al., 2000; Bentayeb et al., 2015).

c See Appendix B.3.3. High confidence: (Uba et al., 1989); Medium confidence: (Kriebel et al., 1993; Kriebel et al., 2001; Akbar-Khanzadeh et al., 1994).

d See Appendix B.3.3. High confidence: (Horvath et al., 1988); Medium confidence: (Schoenberg and Mitchell, 1975; Nunn et al., 1990; Neghab et al., 2011; Malaka and Kodama, 1990; Löfstedt et al., 2009; Löfstedt et al., 2011; Levine et al., 1984b; Khamgaonkar and Fulare, 1991; Holness and Nethercott, 1989; Holmström and Wilhelmsson, 1988; Herbert et al., 1994; Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988, 1989).

#### Immune-mediated Conditions, Focusing on Allergies and Current Asthma

As described in Section 3.2.3, the synthesis judgments were based on human studies of long-term formaldehyde exposure and effects on allergic conditions and asthma; acute exposure studies did not contribute to the evidence integration judgments. The long-term human studies on these outcomes were considered separately in dose-response analysis.

##### Allergic conditions

Seven high or medium confidence epidemiology studies in children or adults provide data on measures of allergy-related symptoms (Yon et al., 2019; Norbäck et al., 2017; Neamtiu et al., 2019; Matsunaga et al., 2008; Huang et al., 2017; Billionnet et al., 2011; Annesi-Maesano et al., 2012). As discussed in Section 3.2.3, effect sizes were around 1.2 in children for rhinitis and rhinoconjunctivitis at exposures around 0.04 mg/m^3^ and above (Yon et al., 2019; Annesi-Maesano et al., 2012). Two studies in children did not observe an association with rhinitis at lower exposure levels (Norbäck et al., 2017; Huang et al., 2017). The point estimates of the relative risks in two studies of rhinitis in adults covering a higher exposure range were also around 1.2, but these estimates were highly imprecise and so cannot be interpreted as strong support for an association in this older population (Matsunaga et al., 2008; Billionnet et al., 2011). Stronger associations (approximate RR 2 to 3) were seen in the only study of eczema in adults (Matsunaga, 2008) and in a study in children of a combination of symptoms relating to eye, nose, and skin (Neamtiu et al., 2019). Two of the studies presented exposure-response analyses using formaldehyde exposure categorized in three levels (Annesi-Maesano et al., 2012) or four levels (Matsunaga et al., 2008).

In addition, two medium confidence epidemiology studies in children provide data on exposure and skin prick tests (SPTs) needed to conduct a quantitative analysis (Palczynski et al., 1999; Garrett et al., 1999). However, because of the limitations with respect to the timing of the exposure measure in relation to SPT testing, and the interpretation of SPTs as less informative to the identified hazard than other allergy-related effects (Section 3.2.3), these studies are not considered further as a basis for quantitation.

Thus, after evaluating the available medium and high confidence studies on allergic conditions for their utility in dose-response analysis (see Table 5-3), two epidemiology studies were advanced for POD derivation (Matsunaga et al., 2008; Annesi-Maesano et al., 2012). A specific strength of the (Annesi-Maesano et al., 2012) study was the 5-day exposure measurement period, which was taken to be a good estimate of the chronic, on-going exposure that would be seen in this non-occupational (i.e., school-based) setting.

Table 5-3 Eligible studies for POD derivation and rationale for decisions to not select specific studies for allergic conditions

Study, endpoint | Dose-response considerations (see methods in Section 2.7) | | | | | Decision
Study, endpoint | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
(Annesi-Maesano et al., 2012), France Rhinoconjunctivitis prevalence | [+] High confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Children ages 9–10; [n] Participation rate 69% | [+] 5-day sampling in classrooms; [+] Continuous exposure; [+] Low median exposure 0.027 mg/m^3^; [n] Exposure range up to 95^th^% of 0.055 mg/m^3^ | [+] ISAAC questionnaire administered by parents (sneezing and runny nose accompanied by itchy eyes out of cold in the past year) | [+] N = 6,683 children 10.7% of girls and 13.1% of boys with rhinoconjuncti vitis; [+] Logistic regression, OR (95% CI) by tertiles of exposure; [+] No other pollutants were associated with rhinoconjunctivitis | POD derived for rhinoconjunctivitis, with no notable concerns.
Other medium or high confidence studies supporting the NOAEL derived from Annesi-Maesano 2012 at relatively low exposures (≤0.04 mg/m^3^)^b^ | N/A | N/A | N/A | N/A | [n] General lack of effects at these exposure levels in the general population support the NOAEL derived from (Annesi-Maesano et al., 2012) | Specific PODs not derived from these studies with similar exposure levels and findings, but more limited study designs, compared to (Annesi-Maesano et al., 2012)
Other medium or high confidence studies supporting the NOAEL derived from Annesi-Maesano 2012 at relatively low exposures (≤0.04 mg/m^3^)^b^ | N/A | N/A | N/A | N/A | Critical concern: [--] Smaller studies or more limited analysis compared to Annesi-Maesano et al., 2012) | Specific PODs not derived from these studies with similar exposure levels and findings, but more limited study designs, compared to (Annesi-Maesano et al., 2012)
(Matsunaga et al., 2008), Japan; Allergy: Self-report medication use for atopic eczema in past 12 months. | [n] Medium confidence; [-] Potential information bias (Some uncertainty due to lack of data pertaining to sensitivity and specificity of outcome assessments); [n] Selection bias possible but differential participation (by formaldehyde exposure and disease status) uncertain; [+] Confounding unlikely | [n] Pregnant women median age ^~^30 years | [n] 24-hr personal sample; [+] Continuous exposure; [+] Low median exposure: 30th% 0.022 mg/m^3^; 60th% 0.033 mg/m^3^; [+] Wide exposure range (up to 0.161 mg/m^3^) | [n] Self-report of medication use for atopic eczema without clarification of type of medicine | [+] N=998 pregnant women; N=57 eczema cases; [+] Logistic regression, OR (95% CI) by 4 exposure categories (<30th, 30th-59th, 60th-89th, and ≥90th %-tiles) | POD derived for eczema, concerns noted
(Matsunaga et al., 2008), Japan; Allergy: Self-report medication use for atopic eczema in past 12 months. | | Some concern: [-] Low participation rate 17% | [n] 24-hr personal sample; [+] Continuous exposure; [+] Low median exposure: 30th% 0.022 mg/m^3^; 60th% 0.033 mg/m^3^; [+] Wide exposure range (up to 0.161 mg/m^3^) | [n] Self-report of medication use for atopic eczema without clarification of type of medicine | Some concern: [-] No estimate of mid-point in highes exposure category | POD derived for eczema, concerns noted
High or medium confidence studies of skin prick tests^c^ | N/A | Critical concern: [--] Uncertainty regarding timing of the exposure measure in relation to SPT testing | N/A | Critical concern: [--] Endpoint far less informative to the identified hazard than other allergy-related effects | N/A | No PODs derived. Critical concerns regarding exposure and outcome as compared to other allergy-related endpoints.

Representing the impact of each factor on the inferred utility of the study for dose-response analysis for this outcome: [+] = increases utility; [n] = neutral effect on utility; [-] decreases utility; [--] critical concern that greatly inhibits utility (gray shading)

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.4 for details).

b Other medium or high confidence studies of rhinitis, rhinoconjuctivitis, or combined eye, nose, and skin symptoms in children (Yon et al., 2019; Norbäck et al., 2017; Neamtiu et al., 2019; Huang et al., 2017); or adults (Matsunaga et al., 2008; Billionnet et al., 2011).

c (Palczynski et al., 1999; Garrett et al., 1999)

##### Asthma prevalence or degree of asthma control

Residential and school-based exposure studies have examined the prevalence of current asthma in relation to formaldehyde exposure in adults and children in relatively low exposure settings. As discussed in Section 3.2.3, five medium or high confidence studies at exposures of ≤ approximately 0.050 mg/m^3^ do not indicate risk at these lower exposure levels. Several of the RR estimates from these individual studies at these exposure levels were limited by low statistical power. The large sample size (N = 6,683 children, ages 9–10 years), relatively long sampling period (5 days), and detailed analytic strategy, including addressing within-city correlations among participants, other pollutants (NO_x_, PM_2.5_, acetaldehyde, acrolein), and stratification by atopy status in (Annesi-Maesano et al., 2012) study are strengths that support its use to derive a NOAEL to represent the set of studies in this relatively low exposure range.

Prevalence of current asthma was also examined in five medium confidence studies in children at higher residential or school exposure levels (> approximately 0.05 mg/m^3^), three of these reported relative risks 2.0 and 3.0, with a wider range seen in the other two studies (RR 1.19 and 12.4). The Krzyzanowski et al. (1990) results for children (5–15 years of age) are based on a relatively large sample size, with a comprehensive exposure assessment protocol (i.e., three locations in the home; two 1-week periods covering two seasons) and categorical analysis using three exposure groups; a limitation is the relatively small number of participants at the higher exposure levels. Other studies in children (Zhai et al., 2013; Neamtiu et al., 2019; Branco et al., 2020) are supportive of the results in of Krzyzanowski et al. (1990) but presented only a dichotomized exposure-response analysis, and so were not used for quantitation. (Liu et al., 2018) was not considered for quantitation because of uncertainty regarding the interpretation of formaldehyde as a single variable representing 4 quartiles.

One of the four medium confidence studies of prevalence of current asthma in adults in higher exposure residential settings (>0.05 mg/m^3^) did not provide quantitative results (Krzyzanowski et al., 1990). Of the remaining two studies, Billionnet et al. (2011), presented only a dichotomized exposure-response analysis, and so was not used for quantitation. The lower three levels of the -level categorical analysis from Matsunaga et al. (2008) contributed to the evaluation of the NOAEL for studies with exposures <0.05 mg/m^3^, while the highest exposure group 0.058–0.161 compared to <0.022 mg/m^3^) was considered as supportive of the POD derived from Krzyzanowski et al. (1990).

The collection of occupational studies (see Section 3.2.3) provides a strong basis for inferences regarding asthma risk at relatively high exposures (e.g., 0.1 to >0.5 mg/m^3^) (Malaka and Kodama, 1990; Herbert et al., 1994; Fransman et al., 2003). However, there would be considerable uncertainty in a POD derived from these studies, identified as a LOAEL, given the dichotomous analyses used to examine associations and the wide variability in exposure measures within each of these studies. Therefore, PODs were not determined using the occupational studies.

EPA identified two studies that examined degree of asthma control in children with asthma in relation to formaldehyde measures in the home (Venn et al., 2003; Dannemiller et al., 2013). Analysis was conducted using four categories of exposure in Venn et al. (2003), based on 3-day exposure measures taken in the home and daily symptom diaries kept for one month among children with persistent wheeze; this 3-day sample was taken to be a good estimate of the ongoing exposure relevant to the symptom diary. Dannemiller et al. (2013) compared mean exposure levels (based on 30 minute samples) in two groups (those with very poor control and all others, based on a five-question survey about symptom control in the past 4 weeks). The larger sample size, longer sampling period, and more detailed exposure-response analysis makes Venn et al. (2003) a stronger basis for providing a POD. Additional adjustment of regression models for dampness or other exposures including visible mold, total VOCs, or NO_2_, did not affect formaldehyde results, reducing the likelihood of residual confounding by coexposures.

Thus, after evaluating the available medium and high confidence studies on prevalence of current asthma or control of asthma symptoms for their utility in dose-response analysis (see Table 5-4), three epidemiology studies were advanced for POD derivation (Venn et al., 2003; Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012).

Table 5-4 Eligible studies for POD derivation and rationale for decisions to not select specific studies for current asthma prevalence and asthma control

Study, endpoint | Dose-response considerations (see methods in Section 2.7) | | | | | Decision
Study, endpoint | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Prevalence of Current Asthma
(Annesi-Maesano et al., 2012), Allergy: Rhinoconjunctivitis prevalence; Supported by other residential or school studies with relatively low exposures (≤ approximately 30.05 mg/m^3^)^b^ | [+] High confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Children ages 9–10 years; [n] Participation rate 69% | [+] 5-day sampling in classrooms; [+] Continuous exposure; [+] Low median exposure 0.027 mg/m^3^; [+] Wide exposure range | [+] ISAAC questionnaire Asthma: asthma in past year (wheezing or whistling in the chest or wheezing or whistling in the chest at nighttime or taken asthma treatment in the past year) | [+] N = 6,683 children; [+] Logistic regression, OR (95% CI) by tertiles of exposure with consideration of several other pollutants | POD derived, no notable concerns.
(Krzyzanowski et al., 1990), United States Asthma prevalence Supported by other residential or school studies with relatively high exposures (> approximately 0.05 mg/m^3^)^c^ | [n] Medium confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population with wide spectrum of SES, ethnicity, and ages (including children 6–15 years) | [+] Two 1-week samplings from kitchen, living area, and bedroom; [+] Continuous exposure; [+] Average exposure 26 ppb (32 μg/m^3^); [+] Wide exposure range | [+] American Thoracic Society questionnaire; Doctordiagnosed asthma | [+] N = 298 children; [+] Increased prevalence of asthma in highest exposure category | POD derived. Concern regarding small number of asthma cases noted.
(Krzyzanowski et al., 1990), United States Asthma prevalence Supported by other residential or school studies with relatively high exposures (> approximately 0.05 mg/m^3^)^c^ | [n] Medium confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population with wide spectrum of SES, ethnicity, and ages (including children 6–15 years) | [+] Two 1-week samplings from kitchen, living area, and bedroom; [+] Continuous exposure; [+] Average exposure 26 ppb (32 μg/m^3^); [+] Wide exposure range | [+] American Thoracic Society questionnaire; Doctordiagnosed asthma | Some concern: [-] N = 21 cases of asthma | POD derived. Concern regarding small number of asthma cases noted.
Liu et al. (2018) (China) Asthma prevalence | [n] Medium confidence; [+] Information bias unlikely; [n] Uncertainty regarding selection bias – participation rate not provided, but the “pass rate” of the questionnaire was 100% and equal number of cases and controls.; [+] Confounding unlikely | [+] Children, mean age 10 years | [+] 2-month sampling period in bedroom and living room; [+] Wide range of exposure Median, 75^th^ percentile, maximum: 0.0384, 0.057, 0.142 0 mg/m^3^ | [+] Hospital diagnosis of asthma; current asthma symptoms based on ISAAC questionnaire; responses (2 or more incidents of cough, wheezing, and dyspnea for ≥ 3 consecutive days) | [+] N=180 cases, 180 controls | POD not derived. Critical concern with results utility regarding interpretation of formaldehyde as a single variable representing 4 quartiles.
Liu et al. (2018) (China) Asthma prevalence | | [+] Children, mean age 10 years | [+] 2-month sampling period in bedroom and living room; [+] Wide range of exposure Median, 75^th^ percentile, maximum: 0.0384, 0.057, 0.142 0 mg/m^3^ | [+] Hospital diagnosis of asthma; current asthma symptoms based on ISAAC questionnaire; responses (2 or more incidents of cough, wheezing, and dyspnea for ≥ 3 consecutive days) | Critical concern: [--] Logistic regression, with quartiles of formaldehyde used as a single variable | POD not derived. Critical concern with results utility regarding interpretation of formaldehyde as a single variable representing 4 quartiles.
Occupational studies (exposures > 0.1 mg/m^3^)^d^,^e^; Asthma prevalence | N/A | Critical concern: [--] Worker population does not include susceptible children and “healthy worker” effect likely to be relevant for this outcome. | Critical concern: [--] High exposures compared to other available study designs | N/A | N/A | POD not derived. Critical concerns regarding population and exposure as compared to available residential- and school-based studies.
Asthma Control
Dannemiller et al. (2013); United States; Asthma symptom control | [n] Medium confidence; [+] Information bias unlikely; [n] Selection bias possible but differential participation (by formaldehyde exposure and disease status) uncertain | [+] Children mean age 10.5 years; [n] Participation rate 79% but population not defined | [+] Concurrent with data collection on outcomes; [+] Median 0.044 mg/m^3^ | [n] 5 questions on symptom control in past 4 weeks?? | Some Concerns: [-] small sample size (37 cases); [-] dichotomized exposure analysis | POD not derived. Studies with more robust design and analyses available given concerns with sampling and dichotomized exposure analysis.
Dannemiller et al. (2013); United States; Asthma symptom control | [n] Medium confidence; [+] Information bias unlikely; [n] Selection bias possible but differential participation (by formaldehyde exposure and disease status) uncertain | [+] Children mean age 10.5 years; [n] Participation rate 79% but population not defined | Some concern: [-] 30 minute sample | [n] 5 questions on symptom control in past 4 weeks?? | Some Concerns: [-] small sample size (37 cases); [-] dichotomized exposure analysis | POD not derived. Studies with more robust design and analyses available given concerns with sampling and dichotomized exposure analysis.
(Venn et al., 2003), United Kingdom; Asthma symptom control | [+] High confidence; [+] Information bias unlikely; [+] Selection bias and confounding unlikely | [+] Children ages 9–11 years; [+] Initial participation rate 85%; [n] Follow-up participation rate 54% | [+]3-d sample in bedroom; [+] Concurrent with data collection on outcomes; [+] Median 0.022 mg/m^3^; 75th percentile 0.032 mg/m^3^ | [+] Symptom frequency: One month daily diaries recording symptoms, including daytime and nighttime wheezing, chest tightness, breathlessness, and cough, each measured on 0 to 5 scale. | [+] N=193 cases; [+] Logistic regression, OR (95% CI) by quartile of exposure | POD derived, no notable concerns.

Representing the impact of each factor on the inferred utility of the study for dose-response analysis for this outcome: [+] = increases utility; [n] = neutral effect on utility; [-] decreases utility; [--] critical concern that greatly inhibits utility (gray shading)

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.4 for details).

b Other supportive high and medium confidence studies with low (≤ approximately 0.05 mg/m^3^) residential or school exposure levels: (Venn et al., 2003; Palczynski et al., 1999; Kim et al., 2011); and the lower three exposure groups in Matsunaga et al. (2008).

c Other supportive medium confidence studies with high (> approximately 0.05 mg/m^3^) residential or school exposure levels: (Zhai et al., 2013; Neamtiu et al., 2019; Branco et al., 2020; Billionnet et al., 2011); and the highest exposure group in Matsunaga et al. (2008).

d (Malaka and Kodama, 1990; Herbert et al., 1994; Fransman et al., 2003).

#### Respiratory Tract Pathology

The four medium confidence occupational studies in humans provide support for the larger evidence base from the experimental studies in animals (Holmstrom et al., 1989c; Edling et al., 1988; Boysen et al., 1990; Ballarin et al., 1992). However, there would be considerable uncertainty in a POD derived from these studies, identified as a LOAEL, given the dichotomous analyses used to examine associations and the wide variability in exposure concentrations within each of these studies (e.g., 0.1 to >0.5 mg/m^3^). Therefore, PODs were not determined using the occupational studies.

Given the abundance of animal studies examining respiratory tract pathology (see Section 3.2.4), the available long-term exposure studies were prioritized for POD derivation. From amongst the medium or high confidence studies with longer formaldehyde exposure durations, preference was given to those studies without significant concerns about the exposure quality or the sensitivity of the outcome measures.

After evaluating the available medium and high confidence studies on respiratory tract pathology for their utility in dose-response analysis (see Table 5-5), two experimental animal studies were advanced for POD derivation (Woutersen et al., 1989; Kerns et al., 1983).

Table 5-5 Eligible studies for POD derivation and rationale for decisions to not select specific studies for respiratory tract pathology

Study, species | Dose-response considerations (see methods in Section 2.7) | | | | | Decision
Study, species | Study evaluation^a^ | Population or subjects^b^ | Exposure | Outcome measure(s) | Result(s) utility | Decision
Studies in Humans
Occupational Studies^c^ | N/A | N/A | Critical concern: [--] Wide within study variability in exposure levels | N/A | Critical concern: [--] Dichotomous analyses (N/LOAEL approach only) | No POD derived. Critical concerns with exposure and results utility for POD derivation. Far more certain estimates available using animal data.
Animal Studies^d^
(Kerns et al., 1983); (Battelle, 1982); rats | [+] High confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [+] 2-year exposure | [+] Good tissue sampling | [+] Large N (N = 119-121); [+] Detailed data (severity; lesion level) | POD derived, no notable limitations.
(Kerns et al., 1983); (Battelle, 1982); mice | [n] Medium confidence; [+] Good exposure quality | [n] Mice appropriate for outcome | [+] 2-year exposure | Some concern: [-] Limited tissue sampling | [+] Large N (N = 119-121) | No POD derived. Critical concern with results reporting for POD derivation.
(Kerns et al., 1983); (Battelle, 1982); mice | [n] Medium confidence; [+] Good exposure quality | Some concern: [-] Survival to 18 mo. < 33% | [+] 2-year exposure | Some concern: [-] Limited tissue sampling | Critical concern: [--] Lesion incidence or severity NR | No POD derived. Critical concern with results reporting for POD derivation.
(Woutersen et al., 1989), rats | [+] High confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [+] 2-year exposure | [+] Good tissue sampling | [n] N = 30 | POD derived, limitations noted.
(Woutersen et al., 1989), rats | [+] High confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [+] 2-year exposure | [+] Good tissue sampling | Some concern:; [-] Limited severity data; [-] High baseline incidence | POD derived, limitations noted.
(Appelman et al., 1988), rats | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | Some concern:; [-] 2-month exposure; [-] Wide dose spacing (0, 0.1, 1.2, 12 mg/m3) | [+] Good tissue sampling | Some concern:; [-] Small N (10-20); [-] Limited data (on severity) | No POD derived. More limited than other available studies given concerns with results and exposure.
(Kamata et al., 1997), rats | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome | [+] 2-year exposure | [+] Good tissue sampling | Some concern:; [-] Small N (<10) for some data; [-] Limited severity data; [-] Neoplastic lesions present | No POD derived. More limited than other available studies given concerns with results and exposure.
(Kamata et al., 1997), rats | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome | Some concern: [-] Methanol co-exposure | [+] Good tissue sampling | Some concern:; [-] Small N (<10) for some data; [-] Limited severity data; [-] Neoplastic lesions present | No POD derived. More limited than other available studies given concerns with results and exposure.
(Sellakumar et al., 1985), rats | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome; [n] Males only considered okay for this outcome | [+] Lifetime exposure | [+] Good tissue sampling | [+] Large N (N = 100) | No POD derived. More limited than other available studies given concerns with results and exposure.
(Sellakumar et al., 1985), rats | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome; [n] Males only considered okay for this outcome | Some concern:; [-] Likely coexposure to kerosene; [-] Single exposure level | [+] Good tissue sampling | Some concern: [-] Limited severity data | No POD derived. More limited than other available studies given concerns with results and exposure.
(Dalbey, 1982), hamsters | [n] Medium confidence; [+] Good exposure quality | Critical concern: [--] Hamsters less sensitive than other animal models | [+] Chronic exposure | [n] Adequate tissue sampling (note: only two nasal sections) | Some concern: [-] Limited severity data | No POD derived. Critical concerns with animals and exposure used.
(Dalbey, 1982), hamsters | [n] Medium confidence; [+] Good exposure quality | Critical concern: [--] Hamsters less sensitive than other animal models | Critical concern: [--] Single, high exposure level (12 mg/m^3^) | [n] Adequate tissue sampling (note: only two nasal sections) | Some concern: [-] Limited severity data | No POD derived. Critical concerns with animals and exposure used.
(Feron et al., 1988), rats | [+] High confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | Critical concern:; [--] High levels and wide spacing (0, 11, and 24 mg/m3); [--] 3-week exposure | [+] 2-year follow-up measures; [+] Good tissue sampling | Some concern: [-] No interim sacrifice data (only recovery data) | No POD derived. Critical concern with exposure.
(Rusch et al., 1983), rats, hamsters, or monkeys | [n] Medium confidence; [+] Good exposure quality | [+] Monkeys better represent human anatomy | [+] 22 hr/d | Some concern: [-] Limited tissue sampling (data only presented for one nasal section) | Critical concern:; [-] Effects only at highest dose; [--] Combined lesions only; [-] Limited severity data | No POD derived. Critical concern with results utility for POD derivation.
(Rusch et al., 1983), rats, hamsters, or monkeys | [n] Medium confidence; [+] Good exposure quality | [+] Monkeys better represent human anatomy | Some concern:; [-] Narrow, low exposure range; [-] 6-week exposure; [-] Controls differ for different exposures | Some concern: [-] Limited tissue sampling (data only presented for one nasal section) | Critical concern:; [-] Effects only at highest dose; [--] Combined lesions only; [-] Limited severity data | No POD derived. Critical concern with results utility for POD derivation.

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.4 for details).

b Testing of males only in experimental animal studies was not considered a limitation for this endpoint. Although not definitive, male animals routinely exhibited increased sensitivity and severity of pathology, with potential physiological explanations for this observed sex difference discussed in Section 3.2.4.

c See Section 3.2.4. All are medium confidence: (Ballarin et al., 1992); (Boysen et al., 1990); (Edling et al., 1988); (Holmstrom et al., 1989c).

d Focusing on the study designs most informative for use in identifying more sensitive and reliable PODs for long-term toxicity values. Specifically, medium or high confidence studies with formaldehyde exposure longer than 13 weeks or of exposure for 13 weeks but with long-term follow-up examinations (see Section 3.2.4).

#### Reproductive and Developmental Toxicity

##### Female reproductive or developmental toxicity

Of the epidemiology studies that evaluated effects on fecundity or spontaneous abortion (see Section 3.3.2), only one study developed individual exposure estimates suitable for dose-response evaluation.

No animal studies of high or medium confidence evaluated these health effects. Thus, after evaluating the available medium and high confidence studies on female reproductive or developmental toxicity for their utility in dose-response analysis (see Table 5-6), only one occupational epidemiology study was advanced for POD derivation (Taskinen et al., 1999).

Table 5-6 Studies for POD derivation and rationale for decisions to not select specific studies for female reproductive or developmental toxicity

Study, species | Dose-Response Considerations (see methods in Section 2.7) | | | | | Decision
Study, species | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Studies in Humans
Taskinen et al. (1999); Time to pregnancy; Fecundity | [n] Medium confidence | [n] Population appropriate for outcome | [n] Detailed exposure assessment | [n] No notable limitations | [+] Large N = 3772 | POD derived for time to pregnancy. Concern noted about potential exposure inaccuracy
Taskinen et al. (1999); Time to pregnancy; Fecundity | [n] Medium confidence | [n] Population appropriate for outcome | Some concern:; [-] Likely some error in exposure assignments and dermal exposure may contribute; [-] Sampling protocol not described | [n] No notable limitations | [+] Large N = 3772 | POD derived for time to pregnancy. Concern noted about potential exposure inaccuracy
Taskinen et al. (1999); Spontaneous abortion | [n] Medium confidence | [n] Population appropriate for outcome | [n] Detailed exposure assessment | Critical Concern: [-] Uncertain applicability of temporal window for | [+] Large N = 3772 | No POD derived. Critical concern with timing of outcome measure.
Taskinen et al. (1999); Spontaneous abortion | [n] Medium confidence | Some concern:; [-] Excluded women with no live birth | Some concern:; [-] Likely some error in exposure assignments and dermal exposure may contribute; [-] Sampling protocol not described | Critical Concern: [-] Uncertain applicability of temporal window for | [+] Large N = 3772 | No POD derived. Critical concern with timing of outcome measure.
Franklin et al. (2019); Birth weight, head circumference | [n] Medium confidence | N/A | Critical concern: [--] Large uncertainties in exposure distribution due to large % < LOD and impact on quantitative results | N/A | N/A | No POD derived. Critical concern with exposure accuracy.
Chang et al. (2017); Birth weight | [n] Medium confidence | N/A | Critical concern: [--] Evidence of confounding by co-exposure | N/A | Some concern: [-] Log transformed formaldehyde concentration | No POD derived. Critical concern with potential coexposure.
(John et al., 1994); spontaneous abortion | [n] Medium confidence | [n] Population appropriate for outcome | Critical Concern: [--] No specific formaldehyde levels reported | Some Concern: [-] Potential biases in evaluating spontaneous abortion | [+] Large N = 6202 | No POD derived. Critical concern with exposure reporting.
Animal Studies
No Medium or High confidence studies in animals were identified. Low confidence studies are typically not used in quantitative analyses when higher confidence studies within a health system are available.

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

##### Male reproductive toxicity

While two medium confidence, well conducted human occupational studies reporting on male reproductive system effects were available, the data were not amenable to dose-response analyses. Five medium or high confidence studies in experimental animals were available, all only testing high formaldehyde levels (> 6 mg/m^3^). Three of these studies were not advanced for POD derivation, primarily due to critical concerns regarding exposure.

Overall, after evaluating the available medium and high confidence studies on male reproductive toxicity for their utility in dose-response analysis (see Table 5-7), two experimental animal studies were advanced for POD derivation (Ozen et al., 2002; Ozen et al., 2005).

Table 5-7 Eligible studies for POD derivation and rationale for decisions to not select specific studies for male reproductive toxicity

Study, species | Dose-Response Considerations (see methods in Section 2.7) | | | | | Decision
Study, species | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Studies in Humans
Wang et al. (2015); sperm parameters in woodworkers | [n] Medium confidence | [n] Population appropriate for outcomes | [+] Detailed exposure assessment; [+] Highly exposed (good exposure contrast) | [n] No notable limitations | [+] Evaluation of exposureresponse; [n] N = 124 | No POD derived. Critical concern with use of results in quantitative analyses.
Wang et al. (2015); sperm parameters in woodworkers | [n] Medium confidence | [n] Population appropriate for outcomes | Some Concern: [-] Concern for confounding (solvents) | [n] No notable limitations | Critical concern: [--] Unable to determine formaldehyde concentration from exposure index metric, so data not amenable to quantitative analyses | No POD derived. Critical concern with use of results in quantitative analyses.
Wang et al. (2012); spontaneous abortion and timeto-pregnancy | [n] Medium confidence | [n] Population appropriate for outcomes | [+] Detailed exposure assessment | Some concern: [-] Potential biases in evaluating spontaneous abortion | [n] N = 302 | No POD derived. Critical concern with use of results in quantitative analyses.
Wang et al. (2012); spontaneous abortion and timeto-pregnancy | [n] Medium confidence | [n] Population appropriate for outcomes | Critical concern: [--] Exposure levels not provided; [-] Concern for confounding (solvents) | Some concern: [-] Potential biases in evaluating spontaneous abortion | Critical concern: [--] Unable to determine formaldehyde concentration from exposure index metric, so data not amenable to quantitative analyses | No POD derived. Critical concern with use of results in quantitative analyses.
Animal Studies
Ozen et al. (2002); Wistar rat Relative testes weight, 13-week exposure | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome; [n] Body weight decreases unlikely to affect outcome | [n] 13-week exposure | Some concern: [-] Relative weight only (for testes, absolute weight is preferred) | Some concern: [-] Small N = 7 | POD derived; multiple concerns noted.
Ozen et al. (2002); Wistar rat Relative testes weight, 13-week exposure | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome; [n] Body weight decreases unlikely to affect outcome | Some concern: [-] Lowest tested exposure level of 12.2 mg/m^3^ | Some concern: [-] Relative weight only (for testes, absolute weight is preferred) | Some concern: [-] Small N = 7 | POD derived; multiple concerns noted.
Ozen et al. (2005); Serum testosterone, Wistar rat, 13- and 4-week exposure | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [n] 13-week exposure | [n] No notable concerns | Some concern: [-] Small N = 6 | POD derived for 13-week exposure; multiple concerns noted.
Ozen et al. (2005); Serum testosterone, Wistar rat, 13- and 4-week exposure | [n] Medium confidence; [+] Good exposure quality | Some concern: [-] Although such effects are expected to be towards the null for this endpoint, uncertain if body weight decreases contributed to magnitude of response | Some concern: [-] Lowest tested exposure level of 6.15 m/m^3^ | [n] No notable concerns | Some concern: [-] Small N = 6 | No POD derived for 4-week exposure. Critical concern with exposure duration.
Ozen et al. (2005); Serum testosterone, Wistar rat, 13- and 4-week exposure | [n] Medium confidence; [+] Good exposure quality | Some concern: [-] Although such effects are expected to be towards the null for this endpoint, uncertain if body weight decreases contributed to magnitude of response | [--] For 4-week exposure experiment, duration is a critical concern. | [n] No notable concerns | Some concern: [-] Small N = 6 | No POD derived for 4-week exposure. Critical concern with exposure duration.
Ozen et al. (2005); Seminiferous tubule diameter, | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [n] 13-week exposure | Critical concern: [--] Sampling insufficiently reported (randomly selected tubules may be oversampled from individual animals within a group) | Critical concern:; [--] Unclear experimental unit (linked to sampling concern); [-] Small N = 7 | No POD derived. Critical concerns with reporting of outcome measures and results.
Ozen et al. (2005); Seminiferous tubule diameter, | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | Some concern: [-] Lowest tested exposure level of 12.2 m/m^3^ | Critical concern: [--] Sampling insufficiently reported (randomly selected tubules may be oversampled from individual animals within a group) | Critical concern:; [--] Unclear experimental unit (linked to sampling concern); [-] Small N = 7 | No POD derived. Critical concerns with reporting of outcome measures and results.
Vosoughi et al. (2012); Vosoughi et al. (2013); Seminiferous tubule diameter, sperm abnormalities, serum T, testes weight, NMRI mice, 10-day exposure | [n] Medium confidence; [+] Good exposure quality | [n] Mice appropriate for outcome | Critical concern:; [--] 10-day exposure; [-] Lowest tested exposure level of 12.3 mg/m^3^ | Some concern: [-] Concern for overt toxicity potentially contributing to responses for some endpoints | [n] N = 12 | No POD derived. Critical concern with exposure.
Sarsilmaz et al. (1999); Leydig cell quantity or nuclear damage, relative testes weight Wistar rat, 4-week exposure | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome | Critical concern:; [--] 4-week exposure; [-] Lowest tested exposure level of 12.3 mg/m^3^ | Some concern: [-] Relative weight only (for testes, absolute weight is preferred) | [n] N = 10 | No POD derived. Critical concern with exposure duration
Sarsilmaz et al. (1999); Leydig cell quantity or nuclear damage, relative testes weight Wistar rat, 4-week exposure | [n] Medium confidence; [n] Adequate exposure quality | [n] Rats appropriate for outcome | Critical concern:; [--] 4-week exposure; [-] Lowest tested exposure level of 12.3 mg/m^3^ | Some concern: [-] Relative weight only (for testes, absolute weight is preferred) | Some concern: [-] Unclear reporting for Leydig cell measures | No POD derived. Critical concern with exposure duration
Sapmaz et al. (2018); Seminiferous tubule measures, Sprague-Dawley rats, 4-and 13-week exposure | [n] Medium confidence; [+] Good exposure quality | [n] Rats appropriate for outcome | [n] 13-week exposure | [n] No notable concerns | Some concern: [-] Small N = 7 | No POD derived. Critical concerns with exposure.
Sapmaz et al. (2018); Seminiferous tubule measures, Sprague-Dawley rats, 4-and 13-week exposure | [n] Medium confidence; [+] Good exposure quality | Some concern: [-] Unreported source of rats | Critical concern:; [--] single exposure level; [-] Lowest tested exposure level of 6.15 mg/m^3^ | [n] No notable concerns | Some concern: [-] Small N = 7 | No POD derived. Critical concerns with exposure.

NR = not reported

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.8 for details).

### 5.1.2 Calculation of PODs

The methods for determining PODs as well as the characterization of the resultant PODs, are detailed in this section.

#### Methods of Analysis

Once the preferred studies and effect(s) were identified within each health domain, PODs are derived for each chosen endpoint using a NOAEL, LOAEL, or BMCL. These PODs are then adjusted (POD_ADJ_), if appropriate, to extrapolate from the estimated or measured exposures to a continuous exposure scenario. For laboratory animal studies, as applicable (U.S. EPA, 1994), this POD_ADJ_ was then converted to a human equivalent concentration (POD_HEC_) using a mathematical calibration. Each of the following organ/health system discussions includes a summary analysis of the strengths and weaknesses for the PODs derived from the individual studies.

#### Sensory Irritation

##### Human residential studies

Table 5-1 provides the rationales for selecting the combination of two complementary sensory irritation studies of formaldehyde exposures in mobile homes (Liu et al., 1991; Hanrahan et al., 1984) for POD derivation, with study details in Table 5-8 below. Hanrahan et al. (1984), a medium confidence study, assessed exposure using two 1-hour average formaldehyde measurements^42^ taken in two rooms in the mobile homes of a group including teenagers and adults and predicted the exposure-response for prevalence of “burning eyes” experienced by the participants since moving into the homes from a logistic regression model that adjusted for age, sex, and smoking. Hanrahan et al. (1984) reported that prevalent symptoms^43^ of burning eyes and eye irritation were significantly associated with in-home formaldehyde exposures, and the authors provided a graphical representation of the best-fitting logistic regression model results of predicted prevalence of “burning eyes” for exposures at 100 ppb increments from 100 to 800 ppb (0.12–0.98 mg/m^3^). The data points were estimated from the published graph (see Appendix D.1.1 for details).

Liu et al. (1991), a medium confidence study, collected data on symptoms during the exposure assessment using a sampling protocol that captured average formaldehyde concentrations in the mobile homes (7-day mean concentration from two rooms). The range of 7-day average formaldehyde concentrations measured by Liu et al. (1991) was comparable to the air concentrations in the homes studied by Hanrahan et al. (1984) (10–460 ppb [0.012–0.57 mg/m^3^]) although this study had a lower LOD of 0.01 ppm (0.0123 mg/m^3^). Although Liu et al. (1991) estimated an exposure-response relation using logistic regression and reported that the effects of formaldehyde exposure were statistically significant, the regression coefficients estimated by the model were not reported. Liu et al. (1991) did report the prevalence of burning eyes for three categorical exposure groups for two seasons (Summer and Winter). More granular exposure data from the same study was published in (Sexton et al., 1986) which provided graphical data for the two seasons when homes were sampled: Summer (Jul/Aug) and Winter (Feb/Mar) and this information was used to refine the exposure estimates corresponding to what was reported in Liu (1991) (see Appendix D.1.1).

EPA extracted the main effect data from both studies (Liu et al., 1991; Hanrahan et al., 1984), transformed the prevalence data to “prevalence odds”^44^ and combined the eight points estimated from the dose-response data from Hanrahan et al. (1984) with the six additional points from Liu et al. (1991) in Figure 5-1 which shows that the two sets of reconstructed dose-response data overlapped between 0.1 and 0.2 ppm formaldehyde concentration (see Appendix D.1.1 for details).

Assuming a background prevalence of “burning eyes” of 3%, EPA fit a cubic polynomial function with the intercept fixed at the log-odds of 0.03 (0.0309), to the combined prevalence odds data and found that a third-degree polynomial function fit with an R^2^ value of 0.998. The following formula describes the functional form for the prevalence odds:

(p)/(1 − p) = 7.8077 * ( exposure )^3^ + 1.6517 * ( exposure )^2^ + 0.7104 * ( exposure ) + 0.0309 (Eq. 5-1)

Figure 5-1 Plot of the prevalence odds by residential concentration-response information from the central estimate of from Hanrahan et al. (1984) combined with complementary information from the central estimate of from Liu et al. (1991)

Blue circles (Hanrahan et al., 1984); Red squares ‘Summer’ Liu et al. (1991); Green triangles ‘Winter’ Liu et al. (1991).

A parallel set of analyses was conducted using the upper bound effect estimates on prevalence from (Hanrahan et al., 1984) and (Liu et al., 1991) to derive a polynomial function of the upper bound prevalence of burning eyes. Assuming a background prevalence of “burning eyes” of 3%, EPA fit a cubic polynomial function with the intercept fixed at the log-odds of 0.03 (0.0309), to the combined prevalence odds data and found that a third-degree polynomial function fit with an R^2^ value of 0.9996. The following formula describes the functional form for the prevalence odds:

(p)/(1 − p) = 57.862 * ( exposure )^3^ − 11.934 * ( exposure )^2^ + 2.4996 * ( exposure ) + 0.0309 (Eq. 5-2)

A BMR representing an extra risk of 10% is generally recommended as a standard reporting level for quantal data. Biological considerations may warrant the use of a BMR of 5% or lower for some types of effects (e.g., frank effects), or a BMR greater than 10% (e.g., for early precursor effects) as the basis of the point of departure (POD) for a reference value (U.S. EPA, 2012). EPA selected a BMR of 10% extra risks of eye irritation and assumed a background prevalence eye irritation of 3% (in the absence of formaldehyde exposure). Farrand (2017) reported that the prevalence of dry eye disease (eye irritation) was 3.4% among those aged 18-49 years and was higher in older groups and lower in younger groups (Farrand et al., 2017). The formaldehyde concentration corresponding to a 13% prevalence of “burning eyes” was calculated from the exposure-response model (see Appendix D.1.1). The 13% prevalence represents a 10% extra risk of sensory irritation as a result of formaldehyde exposure in addition to an assumed background prevalence of 3%. These data were used to derive a BMC_10_ of 0.1403 mg/m^3^ and a BMCL_10_ of 0.070 mg/m^3^ and the BMCL_10_ serves as the POD for the combination of the two studies (see Appendix D.1.1 for details). A background prevalence of 3% was considered to be a reasonable estimate, but the impact of using lower and higher alternative estimates was evaluated.^45^

As noted by others (NASEM, 2023), this combined study analysis takes advantage of the greater range of exposure across the two studies for formaldehyde exposure in mobile homes, different exposure assessment methods (active and passive) with different limits of detection (0.1 ppm and 0.01 ppm), and different time periods of exposure assessment and symptom assessment.

##### Controlled human exposure studies

Based on the rationale for study selection provided in Table 5-1, PODs were determined using two controlled human exposure studies of formaldehyde for which there was medium confidence that evaluated multiple levels of exposure, one by Kulle et al. (Kulle et al., 1987; Kulle, 1993) and another by Andersen and Molhave (Andersen, 1979; Andersen and Molhave, 1983) (see study descriptions in Table 5-8). The selected points of departure (PODs) and most informative comparisons are described below, with additional details in Appendix D.1.1. Overall, the POD of 0.44 mg/m^3^ (0.36 ppm) based on the study by Kulle et al. (Kulle et al., 1987; Kulle, 1993) was selected as the most reliable quantitative estimate of the sensory irritant responses from these two studies of intentionally exposed human volunteers. Although the POD from Anderson and Molhave of 0.12 mg/m^3^ (0.10 ppm) was lower, this POD was associated with lower confidence due to the lack of information on background symptoms without formaldehyde exposure, lack of reporting on symptom severity and incidence of individual irritant symptoms, and other uncertainties (e.g., approximately one-third of participants were smokers) in the reported results.

Kulle et al. (1993) reanalyzed results of a study of eye, nose, and throat irritation among participants exposed to 0, 0.5, 1.0, 2.0, and 3.0 ppm for 3 hours once a week with exposure order randomly assigned (Kulle et al., 1987). The healthy volunteers (19 nonsmokers averaging approximately 26 years of age, including 10 males and 9 females total [note: only 6 females and 4 males were exposed at 0.5 ppm and only 5 males and 3 females were exposed at 3.0 ppm]) all served as their own controls. The sensory irritation symptoms reported by the authors were prevalence of eye irritation or prevalence of nose/throat irritation. The severity of the irritation symptoms was scored using a 4-point scale for none, mild, moderate, and severe effects. For this medium confidence study, two characteristics (one limitation, one strength) of the data were addressed in deriving the POD.

As a limitation of this study design, the same volunteers were exposed to multiple formaldehyde concentrations; thus, responses from individual volunteers were correlated across different exposure concentrations. Typical BMD approaches do not account for such data dependence and the standard BMDL (i.e., at the 95^th^ percentile lower bound) is interpreted as unlikely to reasonably reflect the true variability in these measurements. To address the data dependence and underestimated variation in the BMC, the 99^th^ percentile on the selected model is presented and ultimately selected. This widened confidence interval provides a transparent means of approximating the increased variability expected if independent data measurements were available. The 95^th^ percentile lower bound is provided for all evaluated models for comparative purposes (see Appendix D.1.1 for additional details).

Several approaches were taken to address the presentation of symptoms of varying severity and different sensory irritation symptoms, a strength of this study. The current BMD modeling software is applicable for analysis of a single outcome, but it does not account for differences in outcome severity, and it does not allow for the inclusion of multiple related outcomes in a single analysis. EPA’s categorical regression (CatReg; https://www.epa.gov/bmds/about-catreg) software allows for greater incorporation of these different components of the evidence in the modeling. CatReg provides two basic models to relate the probabilities of the different severity categories to exposure level and exposure duration, taking user-defined covariates into account (e.g., species, gender, target organ, etc.) (U.S. EPA, 2017). The parameters in the models are an intercept term and coefficients of dose and time.^46^

Thus, CatReg was used in dose-response analyses to incorporate information on severity and combine data across different sensory irritation endpoints, to the extent possible. These results were compared with results of modeling using current BMD software for comparative purposes (see additional details, including additional information on CatReg, in Appendix D.1.1). A POD of 0.44 mg/m^3^ (0.36 ppm) was selected for this study based on the 99^th^ percentile BMCL and CatReg modeling of the combination of eye irritation and nose/throat irritation symptoms. Importantly, this POD was interpreted with less uncertainty than the other POD options or incorporated more study-specific information on the subjects’ responses; thus, this was considered to be the most reliable estimate available for this study.

Another experimental study exposed a group of 16 subjects (5 females and 11 males averaging 23 years old, 5 of which were smokers, with one being a heavy smoker) to 0.3, 0.5, 1.0, and 2.0 mg/m^3^ formaldehyde for 5-hour periods with a 2-hour clean air exposure prior to each trial (Andersen, 1979; Andersen and Molhave, 1983). The healthy volunteers all served as their own controls and the order of exposure concentrations was randomized. The sensory irritation symptoms reported by the authors were prevalence of conjunctival redness and/or nose or throat dryness. For this medium confidence study, two limitations in the quantitative use of the reported data needed to be addressed in deriving the POD.

First, the occurrence of irritation symptoms during the clean air exposure was not reported. The background incidence of sensory irritation in the general population, or within healthy adult volunteers such as those participating in this study, is uncertain. An indirect comparison to the population prevalence of dry, irritated, or burning eyes may be a reasonable surrogate for estimating such a background. Although estimates vary, an estimate of the overall background prevalence of diagnosed dry eye disease in U.S. adults is 6.8% (Farrand et al., 2017). When this is restricted to 18–49-year-olds, the authors estimated a background prevalence of 3.4%. This is at the lower end of the background prevalence for such symptoms, which increase with age and vary by gender (with a higher prevalence in females). Thus, BMD modeling was performed assuming different background prevalence. The PODs derived using these different estimates of background varied less than 2-fold (see Appendix D.1.1). Ultimately, use of the lower end (i.e., 3%) of the estimates on the background prevalence of dry eye, is considered appropriate for modeling the broadly healthy populations (20–33-year-old healthy adults in (Andersen, 1979; Andersen and Molhave, 1983)) and variably severe irritation symptoms reported in the available controlled human exposure studies of formaldehyde. Thus, paralleling what was decided for the human residential studies discussed in the prior section, an estimate of 3% background prevalence of irritation during the clean air exposure was selected.

Second, the same volunteers were exposed to multiple formaldehyde concentrations; thus, responses from individual volunteers were correlated across different exposure concentrations. Typical BMD approaches do not account for such data dependence and the standard BMDL (i.e., at the 95^th^ percentile lower bound) is interpreted as unlikely to reasonably reflect the true variability in these measurements. To address the data dependence and underestimated variation in the BMC, the 99^th^ percentile on the selected model is presented and ultimately selected. As discussed for modeling of sensory irritation data reported by Kulle et al. (1993), this widened confidence interval provides a transparent means of approximating the increased variability expected if independent data measurements were available. The 95^th^ percentile lower bound is shown for all evaluated models for comparative purposes.

Thus, BMD software was used to identify both the 95^th^ and 99^th^ percentile lower bounds assuming different levels of background symptoms in the clean-air exposures. A POD of 0.12 mg/m^3^ (0.10 ppm) was selected for this study based on the 99^th^ percentile BMCL assuming a 3% background prevalence (see additional details in Appendix D.1.1).

##### Analysis and Summary of the PODs

Table 5-8 presents the studies used to calculate PODs (bolded) for sensory irritation based on human residential studies and controlled human exposure studies.

Table 5-8 Summary of derivation of PODs for sensory irritation

Study and endpoint | Population | Observed effects by exposure level^a^ | | | | | | POD_ADJ_^b^ (mg/m^3^)
Human Residential Studies
Symptom prevalence Hanrahan et al. (1984) combined with Liu et al. (1991); Medium confidence (both studies) | Teenage and adults (M and F) n = 61, mean age 48 years; +; Adult (M and F), n = 739, Adults 20-64 years in Summer overlapping with n = 587, Adults 20-64 years of in Winter (M and F) | Prevalence data from Liu et al. combined with prevalence data points from Hanrahan et al.; Prevalence data transformed to “Prevalence odds” [p/(1-p)] and fit with a third-degree polynomial model using graphically presented results of logistic regression analysis.; BMC_10_: concentration where an increased prevalence of 10% (BMR) over a 3% background prevalence.; Upper bound on prevalence data points from Liu et al. combined with upper bound prevalence data from Hanrahan et al. and fit with a third-degree polynomial model. See Appendix D.1.1 for details.; BMCL_10_: concentration where an increased upper bound prevalence of 10% (BMR) over a 3% background prevalence. | | | | | | BMC_10_^c^ = 0.14; BMCL_10_^c^ =0.070
Controlled Human Exposure Studies
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | Exposure and proportion (and %) responding (M+F) | | | | | | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | mg/m^3^ | 0 | 0.62 | 1.2 | 2.5 | 3.7 | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | Eye irritation^d^ | 1/19 | 0/10 | 5/19 | 10/19 | 10/10 | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | % | 5 | 0 | 26 | 53 | 100 | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | Nose or throat irritation | 3/19 | 1/10 | 1/19 | 7/19 | 9/10 | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | % | 16 | 10 | 5 | 37 | 90 | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | trend, p < 0.05 | | | | | | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (combined eye irritation and nose or throat irritation) (Kulle et al., 1987; Kulle, 1993); Medium confidence | Nonsmoking, healthy, n = 10–19, mean age 26.3 years; (M and F) | CatReg^e^, analysis, combined endpoints and Probit model selected (both CatReg and standard BMDS modeling were used, with multiple endpoints individually or in combination; see Appendix D.1.1):; CatReg, combined eye irritation and nose or throat irritation (probit) BMC = 0.69 mg/m^3^; CatReg, eye irritation (CLogLog) BMC = 0.98 mg/m^3^; CatReg, nose/throat irritation BMC= model fit unacceptable; BMDS, eye irritation (Probit) BMC = 0.85 mg/m^3^; BMDS, nose/throat irritation (Multistage 3°) BMC = 1.56 mg/m^3^ | | | | | | BMC_10_ = 0.69; BMCL_10_ (95^th^ percentile) = 0.52; BMCL_10_ (99^th^ percentile ^f^ ) = 0.44
Symptom prevalence (conjunctival redness and nose or throat dryness) (Andersen, 1979; Andersen and Molhave, 1983); Medium confidence | Healthy students, n = 16, age 20−33 years, 31.2% smokers; (M and F) | Exposure and proportion (and %) responding (prevalence at the end of exposure) (M+F) | | | | | | BMC_10_ = 0.28; BMCL_10_ (95^th^ percentile) = 0.17; BMCL_10_ (99^th^ percentile ^f^ ) = 0.12
Symptom prevalence (conjunctival redness and nose or throat dryness) (Andersen, 1979; Andersen and Molhave, 1983); Medium confidence | Healthy students, n = 16, age 20−33 years, 31.2% smokers; (M and F) | mg/m^3^ | 0 | 0.3 | 0.5 | 1.0 | 2.0 | BMC_10_ = 0.28; BMCL_10_ (95^th^ percentile) = 0.17; BMCL_10_ (99^th^ percentile ^f^ ) = 0.12
Symptom prevalence (conjunctival redness and nose or throat dryness) (Andersen, 1979; Andersen and Molhave, 1983); Medium confidence | Healthy students, n = 16, age 20−33 years, 31.2% smokers; (M and F) | Symptom prevalence | Not reported | 3/16 | 5/16 | 15/16 | 15/16 | BMC_10_ = 0.28; BMCL_10_ (95^th^ percentile) = 0.17; BMCL_10_ (99^th^ percentile ^f^ ) = 0.12
Symptom prevalence (conjunctival redness and nose or throat dryness) (Andersen, 1979; Andersen and Molhave, 1983); Medium confidence | Healthy students, n = 16, age 20−33 years, 31.2% smokers; (M and F) | % | | 19 | 31 | 94 | 94 | BMC_10_ = 0.28; BMCL_10_ (95^th^ percentile) = 0.17; BMCL_10_ (99^th^ percentile ^f^ ) = 0.12
Symptom prevalence (conjunctival redness and nose or throat dryness) (Andersen, 1979; Andersen and Molhave, 1983); Medium confidence | Healthy students, n = 16, age 20−33 years, 31.2% smokers; (M and F) | BMDS modeling assuming different (background) prevalence for clean air dose (see Appendix D.1.1^g^):; 0% Log-logistic model BMC = 0.26 mg/m^3^; 3% Log-logistic model BMC = 0.28 mg/m^3^; 6% Log-logistic model BMC = 0.30 mg/m^3^; 9% Hill model BMC = 0.45 mg/m^3^ | | | | | | BMC_10_ = 0.28; BMCL_10_ (95^th^ percentile) = 0.17; BMCL_10_ (99^th^ percentile ^f^ ) = 0.12

a Any concentrations reported in publications as ppm have been converted to mg/m^3^.

b These PODs were not adjusted for a 24-hour equivalent concentration because the timing of formaldehyde measurements was concluded to be appropriate to the time frame of reported symptoms. The selected POD for each study is bolded.

c BMC_10_ benchmark concentration at 10% increase in prevalence over an estimated 3% background prevalence. An increase of 10% was selected consistent with EPA guidelines (U.S. EPA, 2012) because the endpoint, burning eyes with mild to moderate severity, was considered a minimally adverse outcome.

d The study reported results in males and females across a 4-scale symptom rating system (none, mild, moderate, severe). The data here reflect pooled findings of any symptom incidence other than none in both males and females from the (Kulle, 1993) publication; the unpooled results are presented in Appendix D.1.1. Note that the authors also report results for a “symptom score difference” (pre- and post-exposure), pooling results across severity levels in the (Kulle et al., 1987) publication; however, these pooled data were not selected for use quantitatively as there was no information on either the underlying within-subject severity information at both timepoints (pre- and post-exposure) or the score calculations.

e EPA’s categorical regression (CatReg; https://www.epa.gov/bmds/about-catreg) software was used in addition to standard BMDS modeling. The selected model used eye irritation data to predict the slope and combined eye and nose/throat irritation data for the intercept. A second modeling combination using nose/throat irritation for the slope and combined irritation data for the intercept yielded a slightly higher POD of 0.59 mg/m^3^ (0.48 ppm) at the 99^th^ percentile. The selected CatReg model results for the combined endpoints were chosen primarily due to the lower POD, although the BMC/BMCL ratio for these results was also lower, indicating a narrower confidence interval and a lower level of uncertainty. See Appendix D.1.1 for additional details.

f The BMD models did not account for the correlated measures between concentration levels (each participant was exposed to each concentration). Therefore, the 95% confidence limit for the BMC estimated by the model is too narrow to use as the POD. A wider confidence interval (i.e., the 99% lower confidence limit) was used as the POD.

g Note: data for males and females were not reported separately.

The BMC_10_ based on the combination of two studies of sensory irritation in mobile homes (Hanrahan et al., 1984) combined with Liu et al. (1991) is 0.140 mg/m^3^ and the BMCL_10_ is 0.070 mg/m^3^. Potential concerns regarding this POD include the short, 1-hour, duration of the measurement of formaldehyde to represent the average exposure, the lack of concurrence of the exposure and outcome ascertainment from (Hanrahan et al., 1984) which accounted for less than 10% of the combined population, and the graphical nature of the results from both studies. However, the combined study population from Hanrahan et al. (1984) and (Liu et al., 1991) is pertinent to the U.S. general population because: (1) the populations were randomly selected from the general population in the study area; (2) the exposure levels were concluded to reflect the usual, relatively constant formaldehyde concentrations in the residences; and (3) exposed individuals included a range of ages (teenagers and adults), men and women, and some with chronic disease. The impact of potential confounding by the presence of coexposures is likely to be minimal. The regression models in both studies adjusted for age, sex, and smoking. The presence of smokers or gas appliances in the home, sources that might contribute to variability in formaldehyde concentrations, were not associated with indoor formaldehyde concentrations. Other emissions released from the same sources as formaldehyde that also might contribute to eye irritation, such as phenols from resins in floor or wall coverings or pinene and terpenes from wood products, were not analyzed. However, a strong exposure-response relationship with formaldehyde concentration was observed by this study, which argues against a large effect by residual confounding by other coexposures.

The PODs based on the two controlled human exposure studies were 0.12 mg/m^3^ (Andersen, 1979; Andersen and Molhave, 1983) and 0.44 mg/m^3^ (Kulle et al., 1987; Kulle, 1993), less than an order of magnitude greater than the POD estimated from residential exposure. The POD based on Kulle et al. (Kulle et al., 1987; Kulle, 1993) is preferred to the estimate based on Andersen and Molhave (Andersen, 1979; Andersen and Molhave, 1983), as explained above. In the context of deriving an RfC for lifetime formaldehyde inhalation, the PODs based on these intentional exposure studies possess several notable limitations as compared to the residential exposure POD because: (1) the study participants were young, healthy volunteers not representative of the age distribution and health status in the general population; (2) the PODs are based on small sample sizes, more subject to random variation; and (3) formaldehyde concentrations were high, imposing substantial uncertainty regarding responses at the low tail of the exposure distribution. However, the utility of the PODs from these two controlled exposure studies may be greater for other, less than chronic, exposure durations (e.g., derivation of an acute RfC).

#### Pulmonary Function

Table 5-2 provides the rationales for selecting the epidemiology study of residential formaldehyde exposure (Krzyzanowski et al., 1990) for POD derivation, which is summarized in Table 5-9 below. Declines in peak expiratory flow rate (PEFR) were associated with increases in 2-week average indoor residential formaldehyde concentrations, with greater declines observed in children (5–15 years of age) compared to adults (Krzyzanowski et al., 1990). This study of effects in a residential population used the most thorough exposure assessment protocol representing the etiologically relevant exposure window and repeated measurements of PEFR, thus enhancing the sensitivity of this study for detecting an effect on pulmonary function. Mean formaldehyde levels were 26 ppb (0.032 mg/m^3^), and more than 84% of the homes had concentrations 40 ppb (0.049 mg/m^3^) and lower. A BMC_10_ of 0.033 mg/m^3^ and BMCL_10_ of 0.021 mg/m^3^ were determined from the regression coefficient from a random effects model of PEFR among children reported (and presented graphically) by the study authors (for details, see Appendix D.1.2). Table 5-9 presents the study used to calculate a POD with the epidemiology data and sequence of calculations leading to the derivation of a POD relating to pulmonary function.

Table 5-9 Summary of derivation of PODs for pulmonary function

Endpoint and reference | Population | Results by exposure level^a^ | BMC and BMCL (mg/m^3^) | POD_ADJ_^b^ (mg/m^3^)
PEFR; Krzyzanowski et al. (1990); Residential, prevalence; High confidence | 202 households, 298 children aged 5−15 years, current asthma prevalence 15.8%;; 613 adults and adolescents > 15 years, 24.4% current smokers, current asthma prevalence 12.9% | Random effects model; decreased PEFR, children −1.28 ± 0.46 L/minute-ppb (95% upper bound −2.04 L/minute-ppb); Formaldehyde concentrations: Mean 0.032 mg/m^3^, maximum 0.172 mg/m^3^ | BMC_10_^c^ 0.033; BMCL_10_^c^ 0.021 | 0.021

a Concentrations reported in publication converted to mg/m^3^.

b The POD was not adjusted for a 24-hour equivalent concentration because formaldehyde is present in all indoor environments and time-activity information for participants was not reported.

c BMC_10_ benchmark concentration associated with a 10% decrease in pulmonary function. A BMR of 10% reduction in PEFR was

##### Analysis and Summary of the POD

The adjusted POD estimated using the results of Krzyzanowski et al. (1990) (0.021 mg/m^3^) was derived from the responses of a randomly selected population of adults and children continuously exposed to formaldehyde in their homes. In this large, population-based sample, the investigators observed a linear relationship between increased formaldehyde exposure and decreased peak expiratory flow rate (PEFR) among children exposed to average concentrations of 0.032 mg/m^3^ (26 ppb), and a stronger response was observed among children with asthma. Krzyzanowski et al. (1990) adjusted for smoking status, environmental tobacco smoke and NO_2_ levels in their analyses; thus, confounding by these coexposures can be ruled out. Further, a strong exposure-response relationship with formaldehyde concentration was observed by this study, which argues against a large effect by residual confounding by other coexposures. This study was able to evaluate associations with relatively constant, low formaldehyde concentrations and used a high-quality exposure measurement protocol, thus, reducing uncertainties for low-dose extrapolation (0.012 to 0.172 mg/m^3^ (Quackenboss et al., 1989c). The average formaldehyde concentrations measured using two one-week sampling periods, some of which were separated by one to several weeks and in different seasons represent the average levels present in the homes during the previous year, and therefore the analysis used the etiologically relevant exposure window for average pulmonary function status in this study population. Average formaldehyde concentrations in these studies were pertinent to those experienced by the general population (the authors reported that more than 84% of the homes had concentrations 40 ppb [0.049 mg/m^3^] and lower). The POD is based on the findings among children and was derived from a regression model that adjusted for important potential confounders including smoking status, environmental tobacco smoke, socioeconomic status, NO_2_ levels, episodes of acute respiratory illness, and the time of day and estimated the interaction between formaldehyde exposure and asthma status.

#### Immune-mediated Conditions, Focusing on Allergies and Current Asthma

##### Allergic conditions

Table 5-3 provides the rationales for selecting the two epidemiology studies of residential- or school-based formaldehyde exposure (Matsunaga et al., 2008; Annesi-Maesano et al., 2012) for POD derivation. NOAELs were identified in each of the two studies selected for POD derivation based on the pattern of risk seen across the exposure groups; the PODs were based on these NOAELs. The study by Annesi-Maesano et al. (2012) used a relatively long exposure period (5 days), and was a very large study in a school-based sample of children in France (n = 6,683) with analysis presented by tertile. Matsunaga et al. (2008) used 24-hour personal samples in a study of 998 pregnant women in Japan. The primary limitation of the Matsunaga et al. (2008) study is that it is conducted only among adults, and so is less able to address the variability in susceptibility that would be anticipated within a population.

##### Current asthma

Table 5-4 provides the rationales for selecting the three epidemiology studies of residential- or school-based formaldehyde exposure (Venn et al., 2003; Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012) for POD derivation. The consistency of the results in the available residential- and school-based exposure studies, and the absence of an increased risk in the study by Annesi-Maesano et al. (2012), a large school-based study (n = 6,683) that used a 5-day sampling period for formaldehyde measurement, strengthens the basis for interpreting this set of studies as indicating an absence of risk of current asthma below 0.05 mg/m^3^. Based on both the study by Annesi-Maesano et al. (2012) and the support from this collection of studies as a whole, EPA selected a NOAEL of 0.042 mg/m^3^ for risk of current asthma in Annesi-Maesano et al. (2012).

The Krzyzanowski et al. (1990) results for children (5–15 years of age) are based on a relatively large sample size, with a comprehensive exposure assessment protocol (i.e., three locations in the home; two 1-week periods covering two seasons). An increased prevalence of current asthma was seen in the highest exposure group in a categorical analysis. The exposure range in this group was 0.075–0.172 mg/m^3^, but the study also notes that few values were above 0.11 mg/m^3^. Based on this information, EPA selected a LOAEL based on the midpoint of this exposure category using a range estimated as 0.075 to 0.11 mg/m^3^ (midpoint of 0.092 mg/m^3^). The estimate for the middle category of exposure was selected as a NOAEL, although there is greater uncertainty in the NOAEL, given the imprecision of the estimate (n with asthma = 1 for this category).

For the selected study on the degree of asthma control in children with asthma by Venn et al. (2003), EPA selected a NOAEL of 0.027 mg/m^3^ (median exposure in the third quartile; no or weak RRs seen below this value) and a LOAEL of 0.041 mg/m^3^ (median exposure in top quartile, for which a two- to three-fold increased risk of symptoms was seen). Venn et al. (2003) did identify an exposure-response relationship for both nighttime symptoms of poor asthma control as OR = 1.40 (95% CI 1.06–1.98) and for daytime symptoms of poor asthma control as OR = 1.45 (95% CI 1.00–1.94). Using the reported OR per quartile exposure from the regression results, and the median exposure values for each quartile (personal communication to EPA (Venn, 2012)), EPA calculated the concentration associated with a 5% increase in prevalence of symptoms above the prevalence observed in the referent group (for details of BMCL calculations, see Appendix D.1.3). A BMR of 5% was selected because asthma attacks are overt effects, generally requiring the use of drugs to control symptoms (i.e., a notably adverse effect) (U.S. EPA, 2012).

##### Analysis and Summary of the PODs

Table 5-10 presents the studies with the epidemiology data and sequence of calculations leading to the derivation of a POD for each data set with effects relating to allergies and asthma.

Table 5-10 Summary of derivation of PODs for allergies and current asthma based on observational epidemiology studies

Endpoint and reference | Population | Observed effects by exposure level | | | | | | POD_ADJ_ (mg/m^3^)
Allergic conditions
Rhinoconjunctivitis (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | Prevalence 12.1%, OR (95% CI) (adjusted); ≤0.0191 mg/m^3^ 1.0 (referent); >0.0191–0.0284 1.11 (0.94, 1.37); >0.0284– ^~^0.055 1.19 (1.03, 1.39); NOAEL selection: 0.024 mg/m^3^, midpoint of second exposure category (corresponding to RR 1.11); LOAEL selection: 0.040 mg/m^3^, midpoint of third exposure category (corresponding to RR 1.19) | | | | | | NOAEL: 0.024; LOAEL: 0.040
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | | | Atopic eczema (5.7% prevalence) | | Allergic rhinitis (14.0% prevalence) | | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | mg/m^3^ | n | OR | (95% CI) | OR | (95% CI) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | <0.022 | 298 | 1.0 | (referent) | 1.0 | (referent) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | 0.023–0.033 | 299 | 1.03 | (0.47, 2.29) | 1.06 | (0.65, 1.73) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | 0.034–0.057 | 301 | 1.11 | (0.50, 2.42) | 0.85 | (0.51, 1.40) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | 0.058–0.161 | 100 | 2.36 | (0.92, 6.09) | 1.17 | (0.60, 2.28) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | (trend p-value) | | | (0.08) | | (0.91) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | 0.058 to 0.161 vs. <0.058 | | 2.25 | (1.01, 5.01) | 1.22 | (0.68, 2.20) | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | per 0.0123 mg/m^3^ | | 1.16 | (0.99, 1.35) | | | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | [Stronger associations seen for atopic eczema in women with no family history of atopy] | | | | | | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Atopic eczema (prevalence); personal monitor-based exposure (24 hours); Matsunaga et al. (2008); Medium confidence | Adult women (pregnancy cohort) with median age 30 years; N = 998 | For atopic eczema NOAEL selection: 0.046 mg/m^3^, midpoint for third exposure category (corresponding to RR 1.11). | | | | | | Atopic eczema NOAEL: 0.046; LOAEL: not identified (data too uncertain)^a^
Prevalence of current asthma/degree of asthma control
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | Exposure (mg/m^3^) | | n ^a^ | OR | (95% CI) | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | ≤0.0191 | | 2,200 | 1.0 | (referent) | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | >0.0191–0.0284 | | 2,200 | 1.10 | (0.85, 1.39) | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | >0.0284– ^~^0.055 | | 2,200 | 0.90 | (0.78, 1.07) | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | ^a^Approximation, based on tertiles, with total n = 6,590 | | | | | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); school-based exposure (5 days); Annesi-Maesano et al. (2012); High confidence | Children ages 9−10 years; (M and F); N = 6,683 | NOAEL selection: 0.042 mg/m^3^, midpoint of third exposure category (corresponding to RR 0.90) | | | | | | NOAEL: 0.042; No LOAEL
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | Exposure (mg/m^3^) | | N | | Proportion with asthma | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | <0.049 | | 248 | | 0.12 | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | 0.049–0.074 | | 24 | | 0.04 | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | 0.075–0.172 | | 21 | | 0.24 | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | (trend p-value) | | | | (0.03) | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | Only a few values were reported to be above 0.11 mg/m^3^. | | | | | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | NOAEL selection: 0.062 mg/m^3^, midpoint of second exposure category | | | | | | NOAEL: 0.062; LOAEL: 0.092
Current asthma (prevalence); residence-based exposure (two 1-week periods); Krzyzanowski et al. (1990); Medium confidence | Children ages 5-15 years; (M and F); N = 298 | LOAEL selection: 0.092 mg/m^3^, based on report that only a few values were above 0.11 mg/m^3^, so estimated midpoint of third category was based on range from 0.075 to 0.11, with midpoint of 0.092 mg/m^3^ | | | | | | NOAEL: 0.062; LOAEL: 0.092
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | Exposure (mg/m^3^) | | N | Proportion | OR | (95% CI) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | Frequent nighttime symptoms | | | | | | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | <0.016 | | 39 | 0.41 | 1.0 | (referent) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.016–0.022 | | 35 | 0.49 | 1.40 | (0.54, 3.62) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.022–0.032 | | 36 | 0.53 | 1.61 | (0.62, 4.19 | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.032–0.083 | | 33 | 0.67 | 3.33 | (1.23, 9.01) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | (trend p-value) | | | | | (0.02) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | per quartile increase | | | | 1.45 | (1.06, 1.98) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | Frequent daytime symptoms | | | | | | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | <0.016 | | 37 | 0.62 | 1.0 | (referent) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.020–0.022 | | 34 | 0.47 | 0.47 | (0.47, 1.25) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.022–0.032 | | 37 | 0.73 | 2.00 | (0.71, 5.65) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | 0.032–0.083 | | 32 | 0.73 | 2.08 | (0.71, 6.11) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | (trend p-value) | | | | | (0.05) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | per quartile increase | | | | 1.40 | (1.00, 1.94) | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | NOAEL selection: 0.027 mg/m^3^, median of third exposure category | | | | | | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013
Asthma control among people with asthma, residence-based exposure (3 days); Venn et al. (2003); High confidence | Children (M and F) ages 9–11 years; N = 194 | LOAEL selection: 0.041 mg/m^3^, median of fourth exposure category (based on correspondence with Dr. Venn) | | | | | | NOAEL: 0.027; LOAEL: 0.041; From regression results: BMCL_5_: 0.013

a Matsunaga (2008) reported a clear effect in the highest exposure group (0.058−0.161 mg/m^3^), but EPA was not able to estimate a measure of central tendency for this interval so the next lower exposure interval was judged to be a NOAEL.

For allergy-related conditions (rhinoconjunctivitis), EPA selected NOAEL and LOAEL values of 0.024 and 0.040 mg/m^3^, respectively, in the Annesi-Maesano et al. (2012) study. A higher NOAEL value (NOAEL = 0.046) was selected based on the study in adults by Matsunaga et al. (2008). The classification of rhinoconjunctivitis by Annesi-Maesano et al. (2012) was the most sensitive and specific of the available measures, and the narrower confidence intervals in this study reflected the larger sample size. No other pollutants (e.g., NO_X_, PM_2.5_, acetaldehyde, acrolein, ETS) analyzed by this study were associated with rhinoconjunctivitis.

For the analysis of prevalence of current asthma, EPA selected a NOAEL of 0.042 mg/m^3^ using the data from Annesi-Maesano et al. (2012) (and supported by other studies examining exposures at <0.05 mg/m^3^), and a NOAEL of 0.062 mg/m^3^ based on the data for children in the study by Krzyzanowski et al. (1990). The NOAEL identified from Krzyzanowski et al. (1990) is less reliable because it was based on only one case and a small number of participants in the selected exposure group. A BMCL_5_ of 0.013 mg/m^3^ was selected based on the data for degree of asthma control among children with asthma (Venn et al., 2003). Venn et al. (2003) used a strong study design, observed an exposure-related trend in response and adjusted the statistical analyses for key confounders, including other indoor exposures (e.g., visible mold, total VOCs, NO_2_, cotinine levels). All three studies were well conducted and are interpreted with high or medium confidence. The study by Annesi-Maesano et al. (2012) is a large study with a relatively long exposure measurement period and is supported by a collection of several other smaller studies (with more imprecise effect estimates) at exposures of <0.050 mg/m^3^, which also indicate no increased risk of current asthma at these lower levels (see Section 3.2.3). The analyses by Annesi-Maesano et al. (2012) were adjusted for age, gender, passive smoking, and paternal or maternal history of asthma or allergic disease; thus, confounding is unlikely. The lower NOAEL for degree of asthma control in children with asthma compared with the NOAELs for increased prevalence of current asthma is interpreted to reflect a greater sensitivity of this more susceptible population.

#### Respiratory Tract Pathology

Table 5-5 provides the rationales for deriving PODs based on exposure-response data from two animal studies on histopathological changes (squamous metaplasia^47^) observed in the nasal passages of F344 rats (Kerns et al., 1983) and Wistar rats (Woutersen et al., 1989).

##### Squamous metaplasia in F344 rat (Kerns et al., 1983)

The results of a large, 2-year bioassay in F344 rats was reported in Kerns et al. (1983) and the supporting Battelle report (Battelle, 1982). In this study, male and female rats were exposed to 2.5, 6.9, and 17.6 mg/m^3^ with interim sacrifices at 6, 12, and 18 months. While Kerns et al. (1983) reported squamous cell metaplasia after inhaled formaldehyde exposure, detailed information on lesion incidence by concentration, duration, and cross-section level was provided in the report (Battelle, 1982). The lesions occurred only in the most anterior region (cross-section Level I) at low concentrations but progressed to more distal parts of the nose (cross-section Levels II–V) at higher concentrations. Additionally, the incidence of squamous metaplasia increased with exposure duration. Section 1.2.4 discusses the incidence of squamous metaplasia in the first five nasal sagittal cross sections of the F344 rat, as reported by Kerns et al. (1983) and Battelle (1982).^48^

The POD presented in Table 5-11 is based on lesions at Level 1 of the rat nasal passages. Extrapolation of the rat BMCL to the human is based on the available dosimetric simulations of formaldehyde flux^49^ to the nasal lining in rats and humans. This assessment uses dosimetry derived from (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) and Overton et al. (2001) when extrapolating risk-related dose from the rat to the human (discussed in detail in Appendix C.1, particularly C.1.12, and Appendix D.1.4), and estimates the impact on the dosimetry modeling using Schroeter et al. (2014).^50^ A POD based on lesions reported at Level 2 in Battelle (1982) can also be modeled. However, formaldehyde flux to the nasal lining on Level 2 was not available and could only be crudely estimated based on the locations of the nasal regions tabulated in Kimbell et al. (2001a), as elaborated further in Appendix C.1. For this reason, only a POD based on the Level 1 data is presented.

In determining the BMR level for the POD, severity scores for the squamous metaplasia data in Battelle (1982) were examined, where provided.^51^ The average severity score was in the range of minimal-to-mild at the lowest dose for both the 18- and 24-month durations for Level 1. This finding supports a BMR of 0.1 extra risk, representing a minimal level of adversity. The 24-month data for Level 1 cannot be modeled because the dose-response relationship rises too steeply (for example, the Weibull model fit rises so steeply that the error on the Weibull model power cannot be bounded). Therefore, the 18-month data, for which incidence rises more gradually, were chosen even though these data would be less preferred over the 24-month exposure data. The fact that the lesion incidences are substantially higher with the longer duration (i.e., 24-month) data indicate that a lower POD would be associated with the 24-month exposure, were those data amenable to modeling.

Interspecies extrapolation of the rat BMCL level to humans was carried out in two steps. First, average flux values in the Level 1 region of the rat corresponding to the rat BMCL derived from the incidence of squamous metaplasia were estimated. Next, the exposure concentration at which any region in the human nose (see Appendix C.1) is exposed to this same level of formaldehyde flux at the inspiratory rate of 15 L/min was estimated from the flux tabulations in Kimbell et al. (2001a), table 3). These estimates are provided in the Table 5-11 below. The flux-based extrapolation results in a value similar to that obtained by applying the principle of ppm equivalence^52^ (see table footnote). The benchmark dose model fits and such details and further elaboration of the human extrapolation are provided in Appendix D.1.4.

Table 5-11 Summary of derivation of POD for squamous metaplasia based on observations in F344 rats (Kerns et al., 1983)

Rat sagittal section | BMR | Rat BMCL_10_ (mg/m^3^) | Flux^a^ (pmol/mm^2^-hr) | Human exposure conc (mg/m^3^) | Adjusted^b^ human exposure conc (mg/m^3^)
Level 1 | 0.10 | 0.448 | 685 | 0.484 | 0.086^c^

a Approximate average flux over nasal lining at this level corresponding to the BMCL using estimates in Kimbell et al. (2001a).

b Adjusted for continuous exposure, (6 hours/24 hours) × (5 days/7 days).

c If extrapolation is based on ppm equivalence instead, value increases by 1.14-fold.

##### Squamous metaplasia Wistar rats (Woutersen et al., 1989)

Woutersen et al. (1989) reported on the nasal histopathology for male Wistar rats exposed to 0.1, 1.2, and 12.1 mg/m^3^ for 28 months. Incidence of squamous metaplasia was reported by concentration and cross-section level (i.e., Level 1–2, 3, 4, and 5–6), with Level 1 as the most anterior region.

Following the determination for squamous metaplasia in F344 rats (Kerns et al., 1983), the same minimal adversity was considered for this effect in Wistar rats and a BMR of 0.10 extra risk was used. A dosimetry model for flux to the nasal lining of the Wistar rat is not available. EPA (U.S. EPA, 2012) concluded that internal dose equivalency in the extrathoracic region for rats and humans is in general achieved through similar external exposure concentrations (i.e., even for highly soluble and reactive gases ppm equivalence is a more appropriate default method for extrapolation than an approach based on adjustment by the ratio of surface area to minute volume). This concept is supported by the analysis described above of data from the squamous metaplasia occurring at Level 1 of the F344 rat nose. In that analysis, the extrapolation was based on site-specific flux in the rat and human and differs from an extrapolation based on ppm equivalence by only a factor of 1.14. Level 1 in that study was in the anterior portion of the nose, and the section levels in the Woutersen et al. (1989) study (see Table 5-12) are even more anteriorly located in the nose; therefore, there is even stronger support in this case for using ppm equivalence as the basis for extrapolation across species. Additional details on the benchmark dose modeling are provided in Appendix D.1.4.

##### Analysis and Summary of the PODs

The POD derivations are summarized in Table 5-12.

Table 5-12 Summary of derivation of PODs for squamous metaplasia based on studies in F344 and Wistar rats (Woutersen et al., 1989; Kerns et al., 1983)

Endpoint and reference | Species/sex | Model | BMR | Rat BMC (mg/m^3^) | Rat BMCL (mg/m^3^) | Human POD^a^_ADJ_ (mg/m^3^)
Squamous metaplasia; Kerns et al. (1983); Battelle (1982); High confidence | F344 rat, M and F | Log-probit | 0.10^b^ | 0.576 | 0.448 | 0.086^c^
Squamous metaplasia; Woutersen et al. (1989); High confidence | Wistar rat, M | Log-probit | 0.10^b^ | 0.821 | 0.459 | 0.082^d^

a POD_ADJ_ is the human equivalent of the rat BMCL duration adjusted (6/24) × (5/7) for continuous daily exposure.

b BMR = 0.10 because the severity of squamous metaplasia, as indicated by the severity scores, was considered minimally adverse.

c Human extrapolation was based on estimates of regional formaldehyde tissue flux modeled in Kimbell et al. (2001a), table 3.

d Human extrapolation was based on ppm equivalence derived from pharmacokinetic principles.

Confidence is high in the two studies used to derive PODs, as both studies were well designed and executed with adequate reporting of data. Kerns et al. (1983; Battelle, 1982) was conducted under Good Laboratory Practice conditions, and the inhalation exposure protocols in both studies were adequately documented and well conducted. The POD from Kerns et al. (1983) is more uncertain, primarily because the calculation involved an extrapolation well below the tested formaldehyde concentrations and the BMCL was based on the 18-month exposure although the response was greater in magnitude after 24 months. Studies with various durations and in multiple species/strains have consistently reported histopathological effects after inhaled formaldehyde exposure. Squamous metaplasia was also observed in humans exposed to formaldehyde levels between 0.1 and 2.5 mg/m^3^ (see Section 3.2.4).

#### Reproductive and Developmental Toxicity

##### Female reproductive or developmental toxicity

Table 5-6 provides the rationales for selecting a single occupational exposure study in humans for POD derivation (Taskinen et al., 1999). Taskinen et al. (1999) presented risk estimates for increased TTP for index pregnancies of women in three exposure categories. The exposure assignments were made for jobs held beginning at least 6 months prior to the index pregnancy to evaluate TTP, the primary endpoint of interest. Taskinen et al. (1999) calculated a fecundity density ratio for the three exposure categories based on 8-hour (time-weighted average) TWA (TWA8) formaldehyde concentrations composed of measured concentrations associated with specific work tasks and reported time spent conducting those tasks in the workplace. TTP was elevated in the high exposure group relative to the unexposed group. EPA selected the middle TWA8 exposure level as a NOAEL.

The mean TWA concentrations for each exposure category needed to be adjusted for background formaldehyde exposures experienced by the employees when they were not conducting work tasks with identified formaldehyde exposure. Notably, the mean exposure (18 ppb TWA8) and lowest reported concentration measured in a work area (10 ppb) in the “low exposed” category were less than the reported average ambient exposures for Finland (21.4 ppb) (Jurvelin et al., 2001). The investigators in Taskinen et al. (1999) appear to have assumed that, while the women were away from their “exposed” work area, their exposure to formaldehyde was zero, not accounting for background occupational exposures and ambient levels of formaldehyde. Therefore, EPA recalculated the mean TWA8 concentrations. These calculations are presented in Table 5-13.

Normally, exposures from occupational studies are adjusted to account for the daily breathing volume appropriate to an environmental (versus occupational) setting and for exposure every day of the year (U.S. EPA, 1994). However, with formaldehyde, there is potential for exposure outside of work from in-home and environmental sources of formaldehyde. Therefore, the POD represents exposure during an 8-hour workday.

Table 5-13 Adjusted time-weighted average formaldehyde exposures for Taskinen et al. (1999)

(A) Proportion of work shift corresponding to the exposure group mean task-level formaldehyde exposure (ppb) and the exposure group daily exposure index (8-hour time-weighted average, TWA8). (B) Recalculation of daily exposure index (TWA8) where background formaldehyde exposure is estimated for work time spent on tasks considered unrelated to occupational use of formaldehyde.

A

Exposure group (n) | Reported mean exposure (TWA8) | | Measured average task-level concentrations (ppb) | | Estimate of work time for formaldehyde-related tasks assuming mean exposure levels
Exposure group (n) | Mean (ppb) | Range | Mean | Range | Percentage of work time^a^ | Hours per 8-hr work shift
Low (119) | 18 | 1–39 | 70 | 10–300 | 26% | 2
Medium (77) | 76 | 40–129 | 140 | 50–400 | 54% | 4.3
High (39) | 219 | 130–630 | 330 | 150–1,000 | 66% | 5.3

a Calculated as mean exposure (ppb, TWA8) divided by mean task-level exposures for the exposure group.

B

Exposure group (n) | Estimate of formaldehyde exposure during formaldehyde-related work tasks | | Estimate of formaldehyde xposure from background levels during the work shift | | Alternative daily exposure index (ppb, TWA8)
Exposure group (n) | Mean (mg/m^3^)^a^ | Percentage of work time in formaldehyde task | Background formaldehyde (ppb) | Percentage of time in tasks unrelated to formaldehyde | Alternative daily exposure index (ppb, TWA8)
Low (119) | 0.086 | 26% | 0.026 | 74% | 0.042
Medium (77) | 0.172 | 54% | 0.026 | 46% | 0.106
High (39) | 0.406 | 66% | 0.026 | 34% | 0.278

a Converted from units of ppb reported in paper.

##### Male reproductive toxicity

Table 5-7 provides the rationales for selecting two studies reporting effects on the male reproductive system in rats for POD derivation (Ozen et al., 2002; Ozen et al., 2005). Both studies exposed the animals to paraformaldehyde via inhalation; thus, the interpretation of the results from these studies was not compromised by possible methanol coexposure as with many other studies that evaluated male reproductive toxicity endpoints. Although the (Ozen et al., 2002; Ozen et al., 2005) studies evaluated a small number of animals (seven and six male rats per group, respectively), the studies were able to detect statistically significant effects and the results did not demonstrate excessive variability. In Ozen et al. (2002), small but statistically significant and dose-dependent decreases (8 to 10% reductions from controls) in testis weight (relative to body weight) were observed after 13 weeks of formaldehyde exposure. Although absolute organ weights are preferred for this measure because testis weights are generally conserved when body weight is decreased, mean body weights were also significantly decreased with exposure; thus, this response pattern suggests that the organ weight decreases were likely due to a direct effect on the testis (note: in this case, decreased relative testis weight is likely an underestimate of the more appropriate decrease in absolute testis weight). In addition, this effect increased with duration of treatment (from 4 to 13 weeks of exposure; (Ozen et al., 2002) and was associated with alterations in testicular zinc, copper, and iron levels (measured in the same study), thus reducing concerns about the small magnitude of effect. For the decreased testis weight at week 13 (Ozen et al., 2002), a LOAEL of 24.4 mg/m^3^ was adjusted for continuous exposure based upon the experimental paradigm to yield a POD_ADJ_ of 5.81 mg/m^3^ (POD_ADJ_ = 24.4 mg/m^3^ × 8 hour exposed per day/24 hours per day × 5 days exposed per week/7 days per week).

In Ozen et al. (2005), statistically significant and dose-dependent decreases in serum testosterone levels (40 to 65% decreases from control values) were observed following 13 weeks of inhalation exposure. At the same exposure levels, significant decreases of 23 to 26% from control were noted in mean seminiferous tubule diameters, an effect that could have been directly related to testosterone decreases. For the decreased serum testosterone at 13 weeks (Ozen et al., 2005), a BMCL_1SD_ of 1.465 mg/m^3^ was calculated. A BMR of 1SD was used in the absence of information to support an alternative BMR, consistent with EPA guidelines (U.S. EPA, 2000). This value was adjusted for continuous exposure based upon the experimental paradigm to yield a POD_ADJ_ of 0.349 mg/m^3^ (POD_ADJ_ = 1.465 mg/m^3^ × 8 hour exposed per day/24 hours per day × 5 days exposed per week/7 days per week).

EPA (U.S. EPA, 2012) indicates that for highly soluble and reactive gases that interact with tissue at the portal of entry or for gases with systemic penetration ppm equivalence is likely to be the most appropriate default method for extrapolation. Accordingly, the human equivalent concentrations (HECs) were thus determined to be 5.81 and 0.349 mg/m^3^ for the PODs from Ozen et al. (2002) and Ozen et al. (2005), respectively.

##### Analysis and Summary of the PODs

The POD for female reproductive or developmental toxicity is described in Table 5-14 and the PODs for male reproductive toxicity are described in Table 5-15.

Table 5-14 Summary of derivation of PODs for reproductive toxicity in females

Endpoint and reference | Population | Observed effects by exposure level | | | | POD (mg/m^3^)
Time-to-Pregnancy in Females
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | Time-to-Pregnancy by Formaldehyde Category; Fecundability density ratio (FDR)^a^ | | | | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | Mean TWA8 (mg/m^3^) | # | FDR^b^ | 95% CI | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | Not exposed | 367 | 1.00 | - | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | 0.042 | 119 | 1.09 | 0.86–1.37 | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | 0.106 | 77 | 0.96 | 0.72–1.26 | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | 0.278 | 39 | 0.64 | 0.43–0.92 | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | FDR = ratio of average incidence densities of pregnancies in exposed compared to employed unexposed women Discrete proportional hazards regression; adjusted for employment, smoking, alcohol consumption, irregular menstrual cycles and # children | | | | NOAEL = 0.106; LOAEL = 0.278
Occupational prevalence; Taskinen et al. (1999); Medium confidence | Adult women, n = 602 | Comparison: index pregnancies that occurred when participants were not employed in exposed workplace | | | | NOAEL = 0.106; LOAEL = 0.278

Abbreviations: TWA8 = 8-hour time-weighted average; FDR = false discovery rate; NOAEL = no-observed-adverse-effect level; LOAEL = lowest-observed-adverse-effect level.

a Concentrations converted to mg/m^3^.

b TWA8 reported by authors was recalculated by EPA to account for background formaldehyde exposure while working in “nonexposed” work areas.

Table 5-15 Summary of derivation of PODs for reproductive toxicity in males

Endpoint and reference | Species/sex | Model | BMR (mg/m^3^) | BMC (mg/m^3^) | BMCL (mg/m^3^) | POD_ADJ_ (mg/m^3^)
Ozen et al. (2002); Decreased relative testis weight (13 week); Medium confidence | Rat/M | LOAEL (24.4 mg/m^3^)^a^ | N/A | N/A | N/A | 5.81
Ozen et al. (2005); Decreased serum testosterone (13 week); Medium confidence | Rat/M | Power | 1 SD | 1.935 | 1.465 | 0.349

a BMD modeling at both 10%RD and 1SD were unsuccessful (see Appendix D.1.5). As decreased weights (i.e., a statistically significant decrease of 7.7%) were observed at the lower dose of 12.2 mg/m^3^, the lower dose could not be reasonably supported as a NOAEL.

For female reproductive or developmental toxicity, a POD was identified based on the findings of Taskinen et al. (1999). The study was well-conducted, a robust exposure assessment was used, and the data analysis was adjusted for other risk factors and workplace exposures that could be associated with developmental toxicity. However, because the study evaluated an occupational cohort, generalization to the entire general population is more uncertain. Stratification by use of gloves (yes/no) indicated that women who did not use gloves had a lower FDR. The stronger association among this group implies that dermal absorption might have resulted in a greater response. Therefore, the level of certainty concerning the value of the NOAEL associated solely with inhalation exposure is lessened.

For male reproductive toxicity, the lowest formaldehyde concentration tested in Ozen et al. (2002) was 12.2 mg/m^3^, and in Ozen et al. (2005) was 6.2 mg/m^3^ and both studies had small sample size (N = 6–7 male rats/group). Otherwise, however, both (Ozen et al., 2002; Ozen et al., 2005) studies were well conducted and interpreted with medium confidence, and the observed responses in each study were statistically significant, dose-dependent, and supported by the larger body of animal study data for formaldehyde. Nevertheless, while some rodent studies in the formaldehyde database demonstrated testis (and epididymal) weight deficits coherent with the observed histopathological changes in these organs, there were inconsistencies in organ weight changes across studies that complicate interpretation. Further, the reporting of only relative testes weight rather than the preferred metric of absolute weight is an added uncertainty, although this does mitigate concerns regarding the influence of systemic toxicity on this endpoint. In addition to the high formaldehyde exposure levels and lack of absolute organ weights noted above for Ozen et al. (2002), an inability to successfully model the data represents another uncertainty. For the other POD from Ozen et al. (2005), while two studies observed treatment-related decreases in serum testosterone, evidence of testosterone decreases in the absence of systemic toxicity (observed or inferred) is not available. As significant systemic toxicity is likely to have an impact, potentially a large impact, on serum testosterone levels, the uncertainty in this POD is considered to be greater than the uncertainty associated with the POD based on the organ weight changes in Ozen et al. (2002).

### 5.1.3 Derivation of Candidate Reference Concentrations

In this section, the PODs (either POD_ADJ_ or POD_HEC_) calculated in Section 5.1.2 were used to derive candidate reference concentrations (cRfCs). These derivations are presented according to the specific uncertainty factors (UFs) applied (to reduce redundancy for similar decisions across health effects); the resultant cRfCs are then organized in a table and figure according to health effect. The text below explains the rationale for the UFs that are applied for each candidate RfC; the implementation of those decisions is most easily seen by looking at Table 5-16 that immediately follows the explanatory text.

#### Methods of Analysis

A series of five UFs were applied to each of the PODs developed for each endpoint/study, specifically addressing the following areas of uncertainty: interspecies uncertainty (UF_A_) to account for animal-to-human extrapolation, and consisting of equal parts representing toxicokinetic and toxicodynamic differences; intraspecies uncertainty (UF_H_) to account for variation in susceptibility across the human population (see Section 4.1), and the possibility that the available data may not be representative of individuals who are most susceptible to the effect; LOAEL-to-NOAEL uncertainty (UF_L_) to estimate an exposure level where effects are not expected when a POD is based on a LOAEL; subchronic-to-chronic uncertainty (UF_S_) to account for the uncertainty in using subchronic studies to make inferences about lifetime exposure, and to consider whether lifetime exposure would have effects at lower levels (e.g., for studies other than subchronic studies); and database uncertainty (UF_D_) to account for database deficiencies if an incomplete database raises concern that further studies might identify a more sensitive effect, organ system, or lifestage. The application of these UFs (i.e., assigning a value) was based on EPA’s Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002).

##### UF_A_ interspecies uncertainty: animal-to-human variation

- For the 10 candidate RfCs derived from human epidemiology studies, an interspecies uncertainty factor (UF_A_) was not applied (i.e., UF_A_ = 1).
- For the candidate RfCs for respiratory tract pathology (squamous metaplasia) and male reproductive toxicity from rat data, an HEC was estimated using either dosimetry modeling (Kerns et al., 1983), (metaplasia) or an assumption of ppm equivalence derived from pharmacokinetic principles (Woutersen et al., 1989), (respiratory pathology); (Ozen et al., 2002; Ozen et al., 2005), (male reproductive toxicity).
  ○ A factor of 3 was then applied to account for residual uncertainties in interspecies extrapolation from the two candidate RfCs for respiratory pathology and the two cRfCs for reproductive toxicity in males derived from rat studies.

##### UF_H_ intraspecies uncertainty: Human variation

- As summarized in Section 4.1, populations or lifestages demonstrated to have potentially increased susceptibility to the health effects of inhaled formaldehyde exposure include children, pregnant women, persons with pre-existing health conditions (particularly respiratory conditions such as asthma), and smokers. The UF_H_ selections below explicitly considered the ability of the selected studies to quantitatively address these potential susceptibilities. This resulted in reduced UF_H_s for several endpoints with quantitative analyses for several potentially susceptible groups, namely children, pregnant women, and asthmatics. In addition, co-exposure to tobacco smoke was considered during the evaluation of the individual studies. Section 4.1 discusses several other possible scenarios that might result in increased susceptibility to inhaled formaldehyde but for which the currently available information is inconclusive. While they may have an impact, these potential susceptibility factors without specific experimental support were not considered quantitatively.
- For five candidate RfCs derived from human epidemiology studies, an intraspecies uncertainty factor (UF_H_) of 3 (i.e., 10^1/2^) was used.
  ○ For the cRfC for sensory irritation in populations with residential formaldehyde exposures using the combined data from Hanrahan et al. (1984) and Liu et al. (1991), a UF_H_ of 3 was used. The identified POD was not based on evaluation of differential susceptibility among subgroups with conditions or characteristic that might contribute to variation in response. However, the combined studies were judged to encompass a sufficiently large number (N = 897 households, combined) of individuals representing a broad range of age, sex, health behavior, occupational status, and health status to partially address increased susceptibility. Notably, quantitative estimates of the individual studies and the combined studies are in close agreement, varying by < 20% (as demonstrated in Appendix D.1.1 and by independent estimation of the BMC_10_ values (NASEM, 2023)), despite the combined studies including more than 10-fold more participants than Hanrahan et al. (1984) alone, and a correspondingly greater representation of potentially susceptible individuals^53^. In addition, although quantitative susceptibility information specific to formaldehyde inhalation-induced sensory irritation is unavailable, the combined studies included large numbers of individuals potentially most susceptible based on understanding of dry eye disease (e.g., women and individuals over 50 have a higher prevalence, with those aged 65+ being < 2-fold more likely to develop disease than 50–64-year-olds) (Farrand et al., 2017). Note that for dry eye disease, younger individuals (under age 18 years) have a lower background incidence due to physiological differences; however, it remains unclear whether this decreased susceptibility applies to formaldehyde-induced stimulation of trigeminal nerve endings in the respiratory epithelium. Taken together, the size and composition of the combined dataset, as well as the stability of the selected POD, supports this value as representative of the response in the general population. However, some residual concern for increased sensitivity in specific groups of individuals remains. Considering the specific examples above as well as the broader evidence synthesis (Section 3.2.1), the evidence supports that the potentially increased sensitivity within any given group is likely to be < 3-fold (and typically less than 2-fold). Thus, a 3-fold factor for the UF_H_ was considered to be reasonably protective of potentially susceptible populations or lifestages.
  ○ For Venn et al. (2003), a UF_H_ of 3 was used because the POD was based on the degree of asthma control in children with asthma, a highly sensitive group. (A UF_H_ of 1 was considered but not used because the number of individuals in the two higher exposure groups was relatively low (n = 31–35), and likely did not characterize all possible human variability.)
  ○ For the POD for decreased peak expiratory flow rates (PEFRs) among children from Krzyzanowski et al. (1990), a UF_H_ of 3 was used with support from the model results reported by the authors. The authors of this study evaluated a model of the association of formaldehyde with PEFR that assessed differences between asthmatic and nonasthmatic children. Multiple observations in the study indicate that a UF_H_ of 3 applied to the endpoint can be expected to be protective of asthmatic children and other susceptible individuals. EPA used the published regression coefficients from the random effects model to calculate the predicted decrease in PEFR from the baseline level (i.e., formaldehyde concentration equal to zero) for each group (for details of the analysis see Appendix D.1.2). At the BMC (i.e., PEFR change of 10% in the entire group), the asthmatic children experienced a decrement in PEFR that was 1.5-fold greater than that of the nonasthmatic children. Further, at the BMCL (0.021 mg/m^3^), which was selected as the POD, the decrease in PEFR among asthmatic children was 10.5% while that in nonasthmatic children was 7.2%. The authors also stated that other characteristics that could affect variability such as acute respiratory illness episodes during the observation period, environmental tobacco smoke in the home, or socioeconomic status (education level of head of household) did not increase sensitivity. All of these observations indicate that a UF_H_ of 3 can be expected to be protective of asthmatic children and other susceptible individuals.
  ○ For rhinoconjunctivitis and current asthma prevalence among children (school exposure) from Annesi-Maesano et al. (2012), a UF_H_ of 3 was used for the POD. Although Annesi-Maesano et al. (2012) did not select the study population based on characteristics that increased susceptibility to formaldehyde’s respiratory effects, childhood is a susceptible lifestage for asthma and allergy, and the sample size of 6,600 children was large enough to have characterized an adequate spectrum of human variability. However, a UF_H_ of 1 was not used because susceptibility among subsets of the study population was not specifically assessed.
  ○ Matsunaga et al. (2008) was a study of pregnant women, a sensitive population for eczema prevalence and an UF_H_ of 3 was used for the POD. An UF_H_ of 1 was not applied because the study participants were adult women and no information was available for other sensitive lifestages, including children, a subgroup with a higher prevalence of eczema compared to adults.
- A UF_H_ of 10 was used for the POD for current asthma prevalence in children (Krzyzanowski et al., 1990), the two PODs for sensory irritation in controlled human exposure studies (Kulle et al., 1987; Andersen and Molhave, 1983), the POD for reduced fecundity in reproductive-age women (Taskinen et al., 1999), and four PODs derived from animal studies (Woutersen et al., 1989; Ozen et al., 2002; Ozen et al., 2005; Kerns et al., 1983).
  ○ For current asthma prevalence among children with residential exposure (Krzyzanowski et al., 1990), a UF_H_ of 10 was used because susceptibility among subsets of the population was not specifically assessed, and the precision of the NOAEL was lower compared to Annesi-Maesano et al. (2012).
  ○ For the two sensory irritation PODs derived from short-term controlled human exposure studies (Kulle et al., 1987; Andersen and Molhave, 1983), as well as the developmental toxicity POD based on reduced fecundity in reproductive-age women in an occupational cohort studied by Taskinen et al. (1999), a factor of 10 was applied to account for variation in the broader human population not represented by occupationally exposed groups or participants in controlled human exposure studies who met the eligibility criteria. Physiological differences that affect sensitivity may become less of a concern for exposure to acute, high concentrations of direct-acting irritants (such as formaldehyde) for the derivation of an acute RfC, which could justify application of a lessor UF_H_ as noted by the NRC (2001); however, this consideration does not apply within the context of chronic exposure.
  ○ For the four cRfCs based on studies in animals, a factor of 10 was applied to account for the limited variability in susceptibility factors encompassed by these typical studies of inbred laboratory animal populations.

##### UF_L_ LOAEL uncertainty: LOAEL-to-NOAEL extrapolation

- A LOAEL-to-NOAEL UF was not applied to the five PODs based on a NOAEL (i.e., UFL = 1).
- For the eight PODs derived from BMD modeling, a factor was not applied in keeping with EPA guidelines (U.S. EPA, 2012). EPA selected a BMR of 10% to identify a POD based on specific studies for several effects: sensory irritation, pulmonary function, and respiratory pathology. A BMR of 5% was selected for the POD identified using the Venn et al. (2003) study for effects on degree of asthma control. A BMR of 1 standard deviation from the control mean was selected for male reproductive toxicity manifest as decreased serum testosterone.
- For the POD based on a LOAEL for decreased relative testis weight as a marker of male reproductive toxicity, a UF = 3 rather than a UF = 10 was selected. Although neither a BMDL or NOAEL could be reliably identified, the selected LOAEL was associated with an 11% decrease in weight, likely only slightly higher than the concentration causing a 10% decrease (the target BMR). Thus, a 3-fold downward extrapolation from the LOAEL was interpreted to reasonably approximate a NOAEL.

##### UF_S_ subchronic uncertainty: extrapolation to chronic exposure

- Three experimental studies in animals evaluated exposures of durations less than a lifetime (Ozen et al., 2002; Ozen et al., 2005; Kerns et al., 1983).
  ○ A factor of 10 was applied to the two PODs for male reproductive toxicity to approximate the potential effect of lifetime exposure, as these effects are not necessarily dependent on a specific exposure window and they are expected to worsen with continued exposure (Ozen et al., 2002; Ozen et al., 2005).
  ○ A factor of 3 was applied to the respiratory tract pathology POD from Kerns et al. (1983) because it was based on 18-month exposure data from that rodent study in lieu of the 24-month exposure data available in the same study. As discussed in Section 3.2.4, there are data to suggest that exposure concentration would be more important to the development of this lesion than duration, although the specifics of this relationship have not been defined. However, the lesion incidences for this particular study were substantially higher with the longer duration data (i.e., 24-month versus 18-month), and thus a lower POD would be expected if the 24-month data could have been modeled. Thus, while use of the 18-month exposure duration is expected to reduce the uncertainty associated with extrapolating to lifetime exposure compared with a shorter duration such as 90 days, this reduction in extrapolation to lifetime was considered incomplete and a factor of 3 was applied, consistent with EPA guidelines [a factor other than 10 may be used, depending on the duration of the studies and the nature of the response (U.S. EPA, 1994, 1998, 2002)].
- For one study in a human population, a UF_S_ of 3 was applied to the POD. Matsunaga et al. (2008) evaluated the occurrence of atopic eczema during the past 12 months in a group of pregnant women and analyzed this outcome in relation to formaldehyde concentrations measured in their homes, which is a less-than-lifetime window of vulnerability. However, this outcome may have been pre-existing in a portion of the study sample and the window of susceptibility may not have been sufficiently represented by the shorter exposure period (Cho et al., 2010). Therefore, a UF_S_ of 1 was not applied.
- For the remaining seven PODs derived from human studies, a UF_S_ of 1 was applied. Three studies were of sensory irritation, which is considered to be predominantly an acute response (Kulle et al., 1987; Hanrahan et al., 1984; Andersen and Molhave, 1983). Notably, the controlled exposure studies by Kulle et al. (1987) and Andersen and Molhave (1983) demonstrate formaldehyde-induced sensory irritation after only brief periods of exposure; thus, these studies would be relevant for estimating the sensory irritant effects resulting from acute formaldehyde exposure. Three studies that were used for PODs for pulmonary function, allergic conditions, current asthma, and asthma control evaluated these outcomes in children and considered an appropriate window of exposure (Venn et al., 2003; Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012). The study of Taskinen et al. (1999) evaluated TTP, which in this review is categorized as a female reproductive or developmental endpoint and the exposure window was considered to be appropriate. Matsunaga et al. (2008) evaluated the occurrence of atopic eczema during the past 12 months in a group of pregnant women and analyzed this outcome in relation to formaldehyde concentrations measured in their homes, which is a less-than-lifetime window of vulnerability.

##### UF_D_ database uncertainty

- A factor to account for database deficiencies was not applied to any of the PODs (i.e., UF_D_ = 1). The formaldehyde database is not considered complete, as important questions remain regarding the potential for formaldehyde inhalation exposure to cause reproductive and developmental toxicity and nervous system effects (both of which demonstrate an incomplete evidence base with methodological limitations). An incomplete database can raise concern that further studies might identify a more sensitive effect, organ system, or lifestage (U.S. EPA, 1991, 1994, 1996, 1998, 2002). However, given the breadth of the literature on formaldehyde toxicity, and given the poor distribution of inhaled formaldehyde to distal sites, an expectation that additional data are likely to reveal systemic effects (i.e., by indirect MOAs) at lower exposure levels than those eliciting adverse respiratory system changes seems unlikely; thus, this assessment uses a database uncertainty factor (UF_D_) of 1.

#### Summary of Candidate Reference Concentrations

Table 5-16 summarizes the application of UFs to each POD from the medium or high confidence studies advanced based on the evaluations described in Section 5.1.1 to derive one or more cRfC(s) in each health effect system. Figure 5-2 presents graphically these cRfCs, composite UFs, and PODs, along with the confidence classification for each cRfC described in the next section (Section 5.1.4).

Table 5-16 Health effects and corresponding derivation of candidate RfCs

Endpoint (reference; population) | POD^a^ (mg/m^3^) | POD basis | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | UF_COMPOSITE_ | cRfC (mg/m^3^)
Sensory Irritation
Eye irritation symptoms (Hanrahan et al., 1984) combined with (Liu et al., 1991); teenage and adult M + F, n = (61+836)=897 households, residential; 3% background prevalence | 0.070 | BMCL_10_ | 1 | 3 | 1 | 1 | 1 | 3 | 0.02
Eye irritation symptoms (Kulle et al., 1987); adult M + F, n = 10, controlled exposure; 3% background prevalence | 0.44 | BMCL_10_ (99^th^-%tile) | 1 | 10 | 1 | 1 | 1 | 10 | 0.04
Eye irritation symptoms (Andersen and Molhave, 1983); adult M + F, n = 16, controlled exposure; 3% background prevalence | 0.12 | BMCL_10_ (99^th^-%tile) | 1 | 10 | 1 | 1 | 1 | 10 | 0.01
Pulmonary Function
Peak expiratory flow rate (Krzyzanowski et al., 1990); Children M + F, n = 298, residential | 0.021 | BMCL_10_ | 1 | 3 | 1 | 1 | 1 | 3 | 0.007
Allergy-related Conditions
Rhinoconjunctivitis prevalence (Annesi-Maesano et al., 2012); children M + F, n = 2,200 at POD, school-based exposure | 0.024 | NOAEL | 1 | 3 | 1 | 1 | 1 | 3 | 0.008
Atopic eczema prevalence (Matsunaga et al., 2008); adult F (pregnant), n = 301 at POD, residential (personal monitor) | 0.046 | NOAEL | 1 | 3 | 1 | 3 | 1 | 10 | 0.005
Asthma
Current asthma prevalence (Annesi-Maesano et al., 2012); children M + F, n = 2,200 at POD, school-based | 0.042 | NOAEL | 1 | 3 | 1 | 1 | 1 | 3 | 0.01
Current asthma prevalence (Krzyzanowski et al., 1990); children M + F, n = 24 at POD, residential | 0.060 | NOAEL | 1 | 10 | 1 | 1 | 1 | 10 | 0.006
Asthma control (Venn et al., 2003); children with asthma M + F, n = 35 at POD, residential | 0.013 | BMCL_5_ | 1 | 3 | 1 | 1 | 1 | 3 | 0.004
Respiratory Tract Pathology
Squamous metaplasia: (Kerns et al., 1983; Battelle, 1982); adult F344 rat M + F, 18-month exposure | 0.086 | BMCL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 0.0009
Squamous metaplasia: (Woutersen et al., 1989); adult Wistar rat, M + F, 28-month exposure | 0.082 | BMCL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 0.003
Female Reproductive and/or Developmental Toxicity
Delayed pregnancy (Taskinen et al., 1999); pregnant F, n = 77 at POD, occupational | 0.106 | NOAEL | 1 | 10 | 1 | 1 | 1 | 10 | 0.01
Male Reproductive Toxicity
Relative testis weight (Ozen et al., 2002); adult Wistar rat, M, 13-week exposure | 5.81 | LOAEL | 3 | 10 | 3 | 10 | 1 | 1,000 | 0.006
Serum testosterone (Ozen et al., 2005); adult Wistar rat, M, 13-week exposure | 0.349 | BMCL_1SD_ | 3 | 10 | 1 | 10 | 1 | 300 | 0.001

Abbreviations: cRfC = candidate reference concentration; UF = uncertainty factor; POD = point of departure; BMC = benchmark concentration; BMCL = benchmark concentration, lower confidence bound; NOAEL = no-observed-adverse-effect level; LOAEL = lowest-observed-adverse-effect level.

a POD may be adjusted (e.g., to continuous exposure; to a human equivalent concentration) (see Section 5.1.2).

Figure 5-2 Candidate RfCs with corresponding PODs and composite UFs

As the PODs reflect exact values, and the cRfCs are rounded to one significant figure, the UF_COMPOSITE_ extrapolation between the two is not always exact. *Shading reflects confidence (i.e., “high” confidence = lightest shading; “low” confidence = darkest shading), as described in Section 5.1.4 below.

### 5.1.4 Selection of Organ- or System-specific Reference Concentrations

This section distills the cRfCs from Table 5-16 for each identified health hazard into a single value representing a level without an appreciable risk of deleterious effects on each particular organ or system during a lifetime. These organ- or system-specific RfCs (osRfCs) may be useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site. For each cRfC, a set of three confidence descriptors (reflecting confidence in the study, the accuracy of the quantitative estimate, and the evidence base available for each hazard) and an overall level of confidence are presented, with a corresponding level of confidence presented for each selected osRfC.

#### Methods of Analysis

EPA selected the osRfC for each specific organ or system using rationales specific to the data and studies for that health area, as described below. In general, studies of human populations with exposures that best represent that of the general population, and human or animal studies that evaluated long-term exposure were preferred, when available, unless a shorter window of susceptibility was appropriate. In addition, cRfCs with lower composite UFs were generally preferred. An osRfC was typically selected from cRfCs from higher confidence studies and higher confidence in the POD estimate used to derive the cRfC. osRfCs were sometimes derived using a method that combined two or more cRfCs.

As described in Section 2.7, an overall confidence level of high, medium, or low (or a combination of two of these terms) was assigned to each cRfC and osRfC. Largely, these classifications were based on the accuracy and reliability of the associated POD and study. The POD confidence classifications are supported by the summary descriptions in Section 5.1.2. Confidence in the POD included considerations of the quality and variability of the exposure assessment in an epidemiology study or the exposure protocols in an animal study. Moreover, higher confidence in the osRfC POD was drawn when the POD was identified close to the range of the observed data and the magnitude of exposure was relevant to those experienced in the general U.S. population. In addition, although less influential to the selected overall confidence classification, a confidence judgment is included to describe the coverage and quality of studies that informed the hazard conclusion for that specific organ/system. The evidence base for different health effects varies in size, coverage of critical endpoints, and quality of the studies; this confidence level generally reflects database completeness for each of the organ systems.

Because the studies that are the basis of each of the osRfCs are interpreted to be representative of the sets of studies available for each of the health outcomes evaluated, the overall hazard determination for each database is presented for each osRfC, noting that these judgments reflect the overall confidence in the findings from the sets of available studies, as compared to the confidence in the individual medium or high confidence studies most amenable to estimating a cRfC (and, by association, an osRfC).

#### Sensory Irritation

The osRfC for sensory irritation of 0.02 mg/m^3^ is based on the cRfC for eye irritation derived using the combined results of Hanrahan et al. (1984) and Liu et a. (1991). The overall confidence in this cRfC (medium-low confidence) was higher than the confidence in the cRfCs based on the controlled exposure studies. The cRfC from Kulle et al. (1987) is interpreted with low-medium confidence and Andersen et al. (1983) with low confidence). As described previously, the population in the combined residential studies was more representative of the general population in terms of demographic characteristics and exposure levels, resulting in higher confidence in the combined studies. There was also less uncertainty in calculating a POD for derivation of a chronic RfC, although uncertainties in the POD estimate from the combined studies did warrant a lower confidence in the POD (medium-low) that drove the overall confidence lower. Specifically, while the POD is based on formaldehyde measurements in the participants’ homes and within the range of the data, there were concerns regarding the timing of outcome evaluation in relation to exposure for one of the two studies and important details (e.g., exposure levels and sample sizes for each prevalence data point) were either unavailable or had to be estimated from published graphs. There is an extensive literature on this response to formaldehyde and the completeness of the database is considered to be high for all cRfCs. Because sensory irritation is an immediate response to exposure, the osRfC is applicable to short-term as well as long-term exposure scenarios.

Table 5-17 Confidence determinations for candidate noncancer toxicity values for sensory irritation

Endpoint, reference, population, exposure type | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence^a^ in cRfC
Prevalence of eye irritation symptoms (Hanrahan et al., 1984) combined with (Liu et al., 1991); teenage and adult (M + F), n = 897 households, residential | 0.07; BMCL_10_ | 3 | 0.02 | Medium-low; - Uncertainty related to the precise correspondence of the window of exposure with the period symptoms were experienced in Hanrahan et al. (1984), partly mitigated by the inclusion of Liu et al. (1991); - Uncertainty in estimating data presented graphically.; - Inability to include any weighting of the data points in the modeling (e.g., based on sample size).; - Uncertainty regarding background prevalence. | Medium; - Medium confidence classification; - Diverse population representative of general population.; - Endpoint directly supports hazard. | High; Extensive evidence base considered to be generally comprehensive and stable.; [Judgment of evidence demonstrates] | Medium-low; Concern regarding
Prevalence of eye irritation symptoms (Kulle et al., 1987) adult (M + F), n = 10 controlled exposure | 0.44; BMCL_10_; [99%] | 10 | 0.04 | Low-medium; - Large uncertainty related to ability to accurately address repeated measures in the same small numbers of individuals, partly mitigated by use of 99^th^%.; - Uncertainty regarding background prevalence. | Low-medium; - Medium confidence classification; - Healthy, adult population unlikely to reasonably represent the general population.; - Endpoint directly supports hazard. | | Low-medium; Concerns regarding generalizability are primary drivers of the confidence classification in the context of chronic RfC derivation.
Prevalence of eye irritation symptoms (Andersen and Molhave, 1983) adult (M + F), n = 16 controlled exposure | 0.12; BMCL_10_; [99%] | 10 | 0.01 | Low; As above, but with additional concern regarding precision of exposure levels due to high variability. | Low; As above, but with additional concern regarding confounding by smoking status. | | Low; Concerns regarding generalizability and confounding are primary drivers of the confidence classification in the context of chronic RfC derivation.

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Pulmonary Function

Data from a study in a residential population exposed over multiple years was used to calculate a cRfC for pulmonary function of 0.007 mg/m^3^ (Krzyzanowski et al., 1990). Overall confidence in this value is high and it was chosen to represent the osRfC. Confidence in the use of the study for RfC derivation is high. The results are generalizable to the general population, and a robust exposure assessment was used based on two one-week average measurements in multiple rooms and the stability of the concentrations between sampling periods was established. The average formaldehyde concentrations are concluded to reasonably represents exposures in the homes during the previous weeks and months (i.e., the etiologically relevant exposure window for pulmonary function status), the etiologically relevant exposure window for average pulmonary function. A strong exposure-response relationship with formaldehyde concentration was observed by this study, which reduces concern that residual confounding by unmeasured coexposures (smoking status, environmental tobacco smoke, and NO_2_ were controlled for) strongly influenced the association. Hence, confidence in the POD value is also high. There is evidence for the association of pulmonary function with formaldehyde exposure from multiple studies at higher exposure levels from occupational studies (both cross-sectional and longitudinal designs) and studies of anatomy students with episodic exposure, as well as a few studies among residential and school populations; however, some uncertainties remain and thus confidence in the evidence base is considered to be medium-high.

Table 5-18 Confidence determinations for candidate noncancer toxicity values for pulmonary function

Endpoint, reference, population, exposure | POD (mg/m^3^) Basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence in cRfC^a^
Peak expiratory flow rate (Krzyzanowski et al., 1990) Children (M + F), n = 298 residential | 0.021; BMCL_10_ | 3 | 0.007 | High; - Reliable exposure assessment representing etiologically relevant time window.; - Well-characterized dose-response relationship addressing potential confounding.; - POD within the range of the data. | High; - High confidence classification; - In potentially susceptible individuals (children); - Population representative of the general population.; - Endpoint directly supports hazard. | Medium-high; Evidence base provides clear support for effects on pulmonary function. However, some unexplained inconsistency across studies remains for some markers and fewer studies were available among residential populations.; [Judgment of evidence indicates] | High; Confidence in the POD and study are primary drivers of the confidence classification.

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Allergic Conditions

Candidate RfCs (cRfCs) for allergy-related conditions were derived based on one study in children (Annesi-Maesano et al., 2012) and one study in adults (Matsunaga et al., 2008). Overall confidence was higher (high-medium) for the study in children than in the study in adults (medium-high) because of the higher specificity of the outcome assessment used in the former study^54^, and thus the cRfC of 0.008 mg/m^3^ from Annesi-Maesano et al. (2012) was selected to represent the osRfC. Both PODs were based on NOAELs and are interpreted with high-medium confidence, primarily due to the inability to derive a BMCL. Although both studies adequately addressed potential confounding, as compared to the study by Matsunaga et al. (2008), the large study of children (n = 6,683) by Annesi-Maesano et al. (2012) was better able to address the variability in susceptibility that would be anticipated within a population. The greater strength of the outcome assessment, length of the exposure assessment protocol (5 days) and generalizability of the study by Annesi-Maesano et al. (2012) were the main reason for the confidence in the study, and the cRfC overall, was interpreted with higher confidence. The completeness of the database relating formaldehyde exposure to allergic sensitization is considered to be medium-high. While the evidence integration judgments were based on consistent findings across a variety of endpoints, populations, and exposure scenarios, important uncertainties remain (Section 3.2.3).

Table 5-19 Confidence determinations for candidate noncancer toxicity values for allergy-related conditions

Endpoint, reference, population, exposure | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence in cRfC^a^
Rhinoconjunctivitis prevalence (Annesi-Maesano et al., 2012); children M + F, n = 2,200 at POD, school-based exposure | 0.024; NOAEL | 3 | 0.008 | High-medium; - No BMCL derived | High; - High confidence classification; - Confounding unlikely; - Generalizable; - Endpoint directly supports hazard. | Medium-high; Allergy-related symptoms were consistently increased across a variety of endpoints, populations, and exposure scenarios; however, the effect sizes were small and other uncertainties remain; [Judgment of evidence indicates] | High-medium; Confidence in the POD and study are primary drivers of the confidence classification
Atopic eczema prevalence (Matsunaga et al., 2008); adult F (pregnant), n = 301, residential | 0.046; NOAEL | 10 | 0.005 | High-medium; - No LOAEL or BMCL derived | Medium; - Medium confidence classification; - Confounding unlikely; - Precise exposure measurement (personal monitor); - Low participation rate; - Less generalizable to susceptible individuals; - Less database support for this specific endpoint as compared to other allergy measures | | Medium-high; Confidence in the POD and concerns regarding ability of the study to address the variability in susceptibility that would be anticipated within a population are primary drivers of the confidence classification

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Prevalence of Current Asthma or Degree of Asthma Control

There were three cRfCs developed for asthma, with two based on the prevalence of current asthma (Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012), and one based on the degree of asthma control (Venn et al., 2003). Although the same evidence integration judgments were drawn, confidence in the evidence base for these outcomes (medium confidence) was lower than confidence in the evidence base for allergic conditions for two reasons. Although the database of studies examining prevalence of current asthma in relation to exposures below 0.05 mg/m^3^ is large and relatively robust, there is a smaller number of studies with exposures between 0.05 and 0.1 mg/m^3^, and there were limitations in these studies (e.g., low statistical power, incomplete reporting of study results and exposure measures). The second factor is the scarcity of data pertaining to asthma control among people with asthma. Although the data available indicates this may be a more sensitive outcome than prevalence of current asthma, there is uncertainty regarding that conclusion because of the limited number of studies examining this endpoint. This affected the overall confidence determinations for these three cRfCs.

The POD based on Annesi-Maesano et al. (2012) was derived from a NOAEL using a large study with a relatively long exposure measurement period and using a method for the outcome assessment recommended by an expert panel consulted by EPA regarding study designs used for studies of asthma,^55^ supported by a collection of several other smaller studies; however, a LOAEL or BMCL were unavailable (i.e., high-medium confidence in the POD) and there were no specific evaluations of the most susceptible individuals (i.e., medium-high confidence in the study), resulting in an overall confidence of medium-high. Overall medium-high confidence was also determined for the study by Krzyzanowski et al. (1990). The NOAEL identified from Krzyzanowski et al. (1990) is considered to be more uncertain (i.e., medium-high confidence in the POD) because it was based on only one case and a small number of participants in the higher exposure group. Confidence in this large study was also medium-high. Although Venn et al. (2003) used a strong study design to assess the degree of symptom control (based on one-month daily symptom diaries) among children with asthma, adjusted the statistical analyses to address key confounders, and observed an exposure-related trend among a susceptible population, asthmatic children (i.e., high-medium confidence in the study), the effect estimates derived by Venn et al. (2003) were less precise because of relatively small group sizes, resulting in medium confidence in the POD and overall medium-high confidence.

Thus, all three cRfCs had the same overall confidence, but each determination was driven by a different type of uncertainty. To account for the different uncertainties in the PODs from the three studies, the median of the three cRfCs, 0.006 mg/m^3^, was selected for the osRfC. Quantitatively, this corresponds to the cRfC value from Krzyzanowski et al. (1990). The overall confidence in the osRfC matches the confidence for each composite cRfC, medium-high.

Table 5-20 Confidence determinations for candidate noncancer toxicity values for current asthma or degree of asthma control

Endpoint, reference, population, exposure | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence in cRfC^a^
Current asthma prevalence (Annesi-Maesano et al., 2012); children M + F, n = 2,200 at POD, school-based | 0.042; NOAEL | 3 | 0.01 | High-medium; - No LOAEL or BMCL derived | Medium-high; - High confidence study; - No evaluation of most susceptible; - Endpoint directly supports hazard. | Medium; The evidence on current asthma is reasonably clear at high and low exposure levels, but few studies were available to inform the important exposure range of 0.5-1.0 mg/m^3^ and the sensitive endpoint of control of asthma symptoms was only sparsely studied; [Judgment of evidence indicates] | Medium-high; Confidence reflects an equal contribution from confidence in the POD, Study, and evidence base.
Current asthma prevalence (Krzyzanowski et al., 1990); children M + F, n = 24 at POD, residential | 0.06; NOAEL | 10 | 0.006 | Medium-high; - Small number of cases; - Wide exposure range and multiple exposure groups | Medium-high; - Medium confidence study; - Large study; - Endpoint directly supports hazard. | | Medium-high; Confidence in the POD (due to few cases) and study are primary drivers of the confidence classification
Asthma control (Venn et al., 2003); children with asthma M + F, n = 35 at POD, residential | 0.013; BMCL_5_ | 3 | 0.004 | Medium; - Imprecise due to small group sizes | High-medium; - High confidence study; - Asthmatic children likely amongst most susceptible; - Concerning severity.; - Less support for this specific endpoint as compared to asthma prevalence | | Medium-high; Confidence in the POD (due to imprecise results) and evidence base on this outcome are primary drivers of the confidence classification

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Respiratory Tract Pathology

Two cRfCs for respiratory tract pathology were derived based on squamous metaplasia observed in anterior rat nasal passages in two studies of long-term exposure. There was no clear basis for selecting either the Woutersen et al. (1989) study or Kerns et al. (1983; Battelle, 1982) study over the other on grounds of confidence in the study methods (both high confidence) or known differences in sensitivity between Wistar and F344 rats. In addition, the PODs were nearly identical and the cRfCs are similar for the two data sets [i.e., cRfCs of 0.0009 for Kerns et al. (1983) and 0.003 for Woutersen et al. (1989), which are comparable given the exposure levels tested in the studies and the limited precision of the calculations]. However, there was lower confidence (low confidence as compared to medium confidence for Woutersen et al. (1989)) in the derivation of the POD from Kerns et al. (1983), which involved an extrapolation well below the tested formaldehyde concentrations. In addition, the cRfC for Kerns et al. (1983) involved the application of a UF for exposure duration. While exposure duration is important to the development of this lesion, such effects appear to be more dependent on exposure concentration (see MOA discussion in Section 3.2.4). Thus, although completeness of the database for respiratory tract pathology is considered high, based primarily on the numerous well-conducted, long-term studies in experimental animals, if a factor describing the concentration-duration relationship^56^ were available for formaldehyde (and interpretable in the context of metaplasia), a data-defined UF could have been applied. These uncertainties contributed to a lower confidence of medium overall for the cRfC based on Kerns et al. (1983; Battelle, 1982) as compared to overall medium-high confidence in the cRfC based on the study by Woutersen et al. (1989). Thus, the medium-high confidence cRfC of 0.003 mg/m^3^ from Woutersen et al. (1989) was selected to represent osRfC for respiratory tract pathology.

Table 5-21 Confidence determinations for candidate noncancer toxicity values for respiratory tract pathology

Endpoint, reference, population, exposure | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence in cRfC^a^
Squamous metaplasia: (Kerns et al., 1983; Battelle, 1982); adult F344 rat (M + F), n = 121/sex/group; 18-month exposure | 0.086; BMCL_10_ | 100 | 0.0009 | Low; - POD for longer, more relevant exposure duration, not possible; - Extrapolation outside of range of data; - Dosimetric evaluation of formaldehyde flux possible; - No exposure levels below 2.5 mg/m^3^ | High; - High confidence study; - Large GLP study; - Endpoint directly supports hazard. | High; Thoroughly studied effect with abundant support from animal studies and confirmatory findings from studies in humans; [Judgment of evidence demonstrates] | Medium; Confidence in the POD and study are primary drivers of the confidence classification
Squamous metaplasia: (Woutersen et al., 1989); adult Wistar rat (M + F), n = 30/group 28-month exposure | 0.082; BMCL_10_ | 30 | 0.003 | Medium; - Smaller study increases variability; - No exposure levels between 1.2 and 11.2 mg/m^3^; - Default dosimetric extrapolation | High; - High confidence study; - No notable limitations (note: while an apparent insensitivity of this strain to nasal tumors was observed, this was not as clear for metaplasia and thus did not reduce confidence); - Endpoint directly supports hazard. | High; Thoroughly studied effect with abundant support from animal studies and confirmatory findings from studies in humans; [Judgment of evidence demonstrates] | Medium-high; Confidence in the POD and study are primary drivers of the confidence classification

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Female Reproductive or Developmental Toxicity

Data from one study of women exposed to formaldehyde in the Finnish woodworking industry are available to derive a cRfC for effects on delayed pregnancy (Taskinen et al., 1999). This cRfC of 0.1 mg/m^3^, interpreted with low-medium confidence overall, was chosen as the osRfC. Confidence in the study for cRfC derivation was medium-low, primarily due to use of a healthy worker population unlikely to address variability in response. Although TTP is a sensitive measure of effects on the reproductive system, confidence in the POD is judged to be low because the high exposure levels required substantial extrapolation and dermal exposure may have augmented the response to inhaled formaldehyde. More complete assessments of developmental endpoints by epidemiology or toxicology studies were not available. Thus, the completeness of the database is considered medium-low. The relevant period for exposure effects on TTP through unrecognized fetal losses or factors controlling the ability to conceive could range from the weeks just prior and after conception, to the entire period of prior exposure during the life of the individual because the mechanisms and events through which formaldehyde may cause this outcome are not known.

Table 5-22 Confidence determinations for candidate noncancer toxicity values for female reproductive or developmental toxicity

Endpoint, reference, population, exposure | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence in cRfC^a^
Delayed pregnancy (Taskinen et al., 1999); pregnant F, | 0.106; NOAEL | 10 | 0.01 | Low; - High exposure requiring large extrapolation; - Likely dermal co-exposure contribution to dose-response | Medium-low; - Medium confidence classification; - Healthy worker population unlikely to reflect variability in the general population or susceptible groups. | Medium-low; Although the evidence was sufficient to identify a potential health hazard, few human studies were available on each endpoint and there were no medium or high confidence animal studies.; [Judgment of evidence indicates] | Low-medium; Confidence in the POD and study are primary drivers of the confidence classification

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

#### Male Reproductive Toxicity

Two cRfCs were derived for male reproductive toxicity, based on two studies in rats from the same research group, (Ozen et al., 2002; Ozen et al., 2005). Both cRfCs were interpreted with low confidence. However, the cRfC derived from Ozen et al. (2002) was considered the stronger of the two candidates for male reproductive toxicity, and thus was chosen to represent the osRfC. Specifically, although the magnitude of the testes weight response in Ozen et al. (2002) was less than that of the testosterone decreases observed in Ozen et al. (2005), there is lower confidence in the POD for decreased testosterone as this endpoint is considered more likely to be affected by the expected overt toxicity (and reflex bradypnea) resulting from the high exposure levels in these studies. The confidence in the PODs for both cRfCs is low, primarily because the lowest formaldehyde concentrations tested in these studies were 6 or 12 mg/m^3^. Confidence in the database is considered low-medium because while there are a number of published studies that evaluated reproductive toxicity in males, the interpretation of study results is complicated by their methodological limitations, the exclusive use of formaldehyde concentrations above 6 mg/m^3^, and lack of data regarding functional endpoints.

Table 5-23 Confidence determinations for candidate noncancer toxicity values for male reproductive toxicity

Endpoint, reference, population, exposure | POD, basis | UF_C_ | cRfC (mg/m^3^) | Confidence in POD | Confidence in Study | Confidence in Evidence Base | Overall Confidence
Relative testis weight (Ozen et al., 2002); adult Wistar rat (M), n = 7; 13-week exposure | 5.81; LOAEL | 1,000 | 0.006 | Low; - No NOAEL or BMCL; - Small magnitude of change at LOAEL | Low; - Absolute testes weight preferred but not reported; - Lowest tested exposure 12 mg/m^3^ | Low-medium; No testing of lower exposure levels or chronic exposure scenarios, most other studies had serious methodological concerns, and available human studies do not provide clear support.; [Judgment of evidence indicates] | Low; Confidence in the POD and study are primary drivers of the confidence classification
Serum testosterone (Ozen et al., 2005); adult Wistar rat (M), n = 6; 13-week exposure | 0.349; BMCL_1SD_ | 300 | 0.001 | Low; - BMCL extrapolation orders of magnitude lower than tested exposure levels | Low^b^; - Overt toxicity expected to affect endpoint; - Lowest tested exposure 6 mg/m^3^ | | Low ^b^; Confidence in the POD and study are primary drivers of the confidence classification

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

b This confidence classification is interpreted as at the lower end of the low confidence category.

#### Summary of Organ- or System-specific RfCs

Table 5-24 Organ- or system-specific RfCs for formaldehyde inhalation

Health effect | Basis reference(s) [species] | UF_C_ | osRfC (mg/m^3^) | Hazard Evidence Integration judgment | Confidence^a^ in osRfC
Sensory irritation | Hanrahan et al. (1984) and Liu et al. (1991) combined [human (M + F, adult, and children)] | 3 | 0.02 | Evidence demonstrates | Medium-low
Pulmonary function | Krzyzanowski et al. (1990) [human (M + F, children)] | 3 | 0.007 | Evidence indicates (likely) | High
Allergy-related conditions | Annesi-Maesano et al. (2012) [human (M + F, children)] | 3 | 0.008 | Evidence indicates (likely) | High-medium
Asthma (prevalence of current asthma/degree of asthma control) | Krzyzanowski et al. (1990) (with co-critical cRfCs^b^) [human (M + F, children)] | 10 | 0.006 | Evidence indicates (likely) | Medium-high
Respiratory pathology | Woutersen et al. (1989) [rat (M + F, adult)] | 30 | 0.003 | Evidence demonstrates | Medium-high
Female or developmental toxicity | Taskinen et al. (1999) [human (F, pregnant adult)] | 10 | 0.01 | Evidence indicates (likely) | Low-medium
Male reproductive toxicity | Ozen et al. (2002) [rat (M, adult)] | 1,000 | 0.006 | Evidence indicates (likely) | Low

Abbreviations: osRfC = organ- or system-specific reference concentration; cRfC = candidate RfC; UF = uncertainty factor; POD = point of departure; M = male; F = female.

a As described in Section 2.7, for hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence).

b Co-critical cRfCs were used quantitatively in the osRfC derivation and support the selected osRfC. Specifically, for asthma, the osRfC represents the median cRfC of the three co-critical cRfCs of comparable confidence and uncertainty [Annesi-Maesano et al. (2012); Krzyzanowski et al. (1990); and Venn et al. (2003)]. Because this median corresponds to the cRfC based on Krzyzanowski et al. (Krzyzanowski et al., 1990), quantitatively this study reflects the osRfC based on the three studies.

### 5.1.5 Selection and Characterization of the Overall Reference Concentration

The following discussion outlines the selection of an overall RfC from among the osRfCs presented in Table 5-24. The overall RfC was chosen to reflect an estimate of continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. The amount of risk between the RfC and the PODs (see Figure 5-3 below for context) from which the RfC is derived is not known.

#### Methods of Analysis

Choice of the overall RfC involves consideration of both the level of certainty in the estimated organ- or system-specific values, as well as the level of confidence in the observed effect(s) (see Figure 5-3). An overall confidence level is assigned to the RfC to reflect an interpretation regarding confidence in the collection of study/studies used to determine the hazard(s) and derive the RfC, the RfC calculation itself, as well as the overall completeness of the database on the potential health effects of formaldehyde exposure.

#### Comparison

Figure 5-3 Organ- or system-specific RfC scatterplot

Organ/system RfCs (osRfCs) represented by larger shapes and that are closer to the top of the graph are interpreted with higher confidence regarding the basis from which the value was derived (see Table 5-24), and with less uncertainty (i.e., lower UFs were applied). Larger shapes indicate higher confidence; solid shapes indicate studies in humans; hollow shapes indicate animal studies. For asthma (i.e., prevalence of current asthma or control of asthma symptoms), the composite UF of 10 reflects the UF_C_ for the cRfC from Krzyzanowski et al. (1990), which quantitatively matches the value selected for the osRfC (see Table 5-24). The dashed line represents the RfC of 0.007 mg/m^3^; the circled osRfCs indicate the cluster of effects selected as the basis for this value.

#### Choice of the Overall RfC

An overall RfC for formaldehyde of 0.007 mg/m^3^ was selected. This value is the median of three osRfCs (0.006, 0.007, and 0.008 mg/m^3^) representing a group of respiratory system-related effects (pulmonary function, allergic conditions, and current asthma prevalence or degree of control) in children,^57^ which together are interpreted with high confidence (see Figure 5-3). These osRfCs are based on cRfCs interpreted with the highest confidence and with the lowest composite uncertainty (see Figure 5-3), although they are not the lowest cRfCs that were derived. The osRfCs for female reproductive or developmental toxicity and sensory irritation, only slightly higher and approximately 3-fold higher than the selected RfC, respectively, were associated with less confidence and therefore not used for the RfC. The osRfCs for respiratory pathology and male reproductive effects, while lower than the RfC, were associated with a larger degree of uncertainty, as reflected by their position along the y-axis, and thus similarly not used for the RfC.

The exposure paradigm used by controlled human exposure studies evaluates an immediate response (i.e., on the order of minutes to hours) to acute formaldehyde exposure and it may be appropriate to use the results from these studies to derive an acute RfC. The evidence base for formaldehyde included results from controlled human exposure studies of formaldehyde inhalation and sensory irritation endpoints, pulmonary function response among healthy or asthmatic individuals, and hyperbronchoreactivity among allergic asthmatics in response to an allergen challenge. Two cRfCs for sensory irritation were derived from short-term controlled human exposure studies (Kulle et al., 1987; Andersen and Molhave, 1983), Generally, pulmonary function measures were not changed by acute exposure in several controlled human exposure studies of healthy or asthmatic volunteers, although small decrements were observed after longer exercise components (15 minutes). Two additional studies did not observe pulmonary function changes in response to acute formaldehyde inhalation but did observe an early phase increase in airway reactivity in response to an allergen challenge indicating a potential exacerbation effect by formaldehyde inhalation on asthma symptoms (Ezratty et al., 2007; Casset et al., 2006). Casset et al. (2006) observed a statistically significant response at lower dust mite amounts with formaldehyde levels of 0.092 mg/m^3^ and mouth breathing only, while Ezratty et al. (2007) observed an increase in a reactivity index in response to a grass allergen challenge (p = 0.06) using a higher formaldehyde concentration (0.5 mg/m^3^).

The RfC is an estimate of exposure that is likely to be without an appreciable risk of adverse health effects over a lifetime (U.S. EPA, 2000). For context, the RfC is higher than most estimates of the formaldehyde concentration in outdoor air and lower than most estimates of the formaldehyde concentrations in indoor air^58^. However, it is important to reiterate that this level is interpreted to be without appreciable risk, even in susceptible individuals. It is also important to note that the RfC does not provide information about the magnitude of the risk of respiratory-related effects that might occur at different concentrations above the RfC (e.g., at 0.02 or 0.03 mg/m^3^). As illustrated in Figure 5-4, nearly all the study-specific findings of effects (e.g., LOAELs, BMCs) were not observed until formaldehyde levels well above the estimated median indoor air concentrations in the U.S., with effects generally being observed at or above 33 μg/m^3^ (0.033 mg/m^3^). One study that contributed to the RfC derivation involved an analysis of the degree of asthma control in children with current asthma (Venn et al., 2003), and the RfC is expected to apply to this susceptible subgroup in the population. Although current asthma symptoms and allergic conditions were not observed in studies of children with exposures less than approximately 0.05 mg/m^3^, at 0.021 mg/m^3^, a 10.5% decrease in PEFR among asthmatic children could be estimated using results of Krzyzanowski et al. (1990). Thus, attributes that increase susceptibility in individuals are expected to play a role in increasing the advent of adverse responses to formaldehyde levels above the RfC (e.g., somewhere between 0.007 and 0.033 mg/m^3^).

Figure 5-4 Illustration of noncancer toxicity value estimations

This figure provides a representation of the estimates from studies supporting the cRfCs and those selected to represent the osRfCs (blue shading). Horizontal lines in the figure reflect the extrapolation process for arriving at points of departure (PODs) and toxicity values (unfilled symbols) in the context of the study-specific evidence for effects (filled symbols; effect magnitude estimated based on study figures, tables, or reported regressions; see previous sections). Note: The x-axis is intentionally not on a linear or log scale so as not to convey a false level of precision. Abbreviations: cRfC = candidate RfC; N/LOAEL = no-/lowest-observed-adverse-effect level; UFs = uncertainty factors; BMCL = benchmark concentration, lower confidence bound. The horizontal arrows indicate that effects continue at higher exposure levels within those studies. *For the studies by Ozen et al., the shaded circles represent adjusted (for continuous exposure) values, not study-specific tested concentrations. Exposure assessments are not part of IRIS assessments (see Appendix A.3 for a background summary on exposure for general context). Draft exposure assessments are underway in EPA’s TSCA Office (see https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-evaluation-formaldehyde#re-findings).

Although the RfC is designed to apply to exposures over a lifetime, the relevant window of exposure for some of the effects observed in the contributing studies may be less than lifetime. For instance, the relevant window of exposure for effects on asthma outcomes is less than lifetime, although the time frame for the control of asthma symptoms (i.e., a few weeks) is expected to be different than that for the prevalence of current asthma symptoms or a decrease in pulmonary function (i.e., the last 12 months).

Table 5-25 Overall RfC for formaldehyde inhalation

Health effects and basis | RfC (mg/m^3^) | Overall confidence
Pulmonary function, allergy-related conditions, and degree of asthma control/prevalence of current asthma in children based on human residential- and school-based studies^a^ | 0.007 | High

a Based on the following studies: Venn et al. (2003); Krzyzanowski et al. (1990); Annesi-Maesano et al. (2012).

#### Uncertainties in the Derivation of the Overall Reference Concentration

Research in experimental animals with regard to two health effects, respiratory tract pathology and male reproductive toxicity, indicates that the overall RfC may not be protective against these hazards. Based on these effects, an alternative RfC of 0.003–0.006 mg/m^3^ would be derived. However, the confidence in this alternative RfC would be lower because uncertainties regarding these osRfCs are greater and the extrapolation from concentrations at which effects were observed in these experimental animal studies was much larger.

The potential for formaldehyde to adversely affect the nervous system, female and male reproduction, as well as development are not well studied, and the systemic effects of inhaled formaldehyde are not well understood. The potential for a localized, immunosuppressive effect in the respiratory tract, with implications for infectious diseases spread through inhalation, is another understudied issue. Additional research in these areas would increase understanding of the spectrum of effects seen with formaldehyde exposure, formaldehyde concentrations that pose a hazard for specific types of effects, and MOAs for these effects.

#### Confidence Statement Regarding the Overall Reference Concentration

An overall confidence level of high, medium, or low is assigned to reflect the level of confidence in the study(ies) and hazard(s) used to derive the RfC, the overall database, and the RfC itself, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). Overall confidence in the RfC is high based on the confidence determinations for the three osRfCs supporting the RfC (see Table 5-25) and there are minimal associated uncertainties (i.e., the UF_C_s for the values supporting the RfC were either 3 or 10). The RfC is based on a spectrum of adverse effects reported in multiple well-conducted studies involving different populations of exposed humans. The study populations were exposed to formaldehyde levels in a residential or school setting, thus requiring no high-to-low exposure extrapolation, and some of the studies focused on sensitive individuals. An extensive literature database supports the hazard conclusions.

### 5.1.6 Previous IRIS Assessment: Reference Value

An inhalation RfC for formaldehyde has not previously been derived. In 1990, an oral reference dose (RfD) of 0.2 mg/kg-day was developed. This value was based on reduced weight gain and histopathology (primarily of the gastrointestinal system) in Wistar rats during a 2-year bioassay in which formaldehyde was administered in the drinking water (Til et al., 1989). A UF_C_ of 100 was applied to the NOAEL to account for inter- and intraspecies differences. This RfD was interpreted with medium confidence, based on high confidence in the principal study and medium confidence in the database.

## 5.2 INHALATION UNIT RISK FOR CANCER

Unit risk estimates for cancer were derived from different data sets available from both epidemiological and experimental animal studies. Quantitative estimates could be derived for two of three cancer types for which the evidence supporting a human health hazard was sufficiently strong (evidence demonstrates): nasal cancers (i.e., nasopharyngeal cancer in human studies; nasal SCC in experimental animal studies) and myeloid leukemia, although there was too much uncertainty in the estimate for myeloid leukemia to incorporate it into the inhalation unit risk (IUR). While the evidence supporting a human health hazard from sinonasal cancer from studies in occupational cohorts and experimental animals also was sufficiently strong to support the derivation of unit risk estimates, no adequate exposure-response data sets were available to derive unit risk estimates.

Section 5.2.1 focuses on the derivation of unit risk estimates for nasal cancers with an examination of sources of uncertainty, and Section 5.2.2 summarizes the attempts to derive unit risk estimates for myeloid leukemia and examines sources of uncertainty. Section 5.2.3 presents a summary of the quantitative estimates obtained from the different data sets and selection of the IUR. Section 5.2.4 describes adjustments to the IUR for assumed early-life susceptibility for cancers with a mutagenic MOA. Finally, Section 5.2.5 provides a summary of the final adjusted unit risk estimate and uncertainties.

The IUR for cancer was ultimately estimated based on the unit risk estimate for extra risk of NPC using the results from an occupational study and cumulative exposure. Because the MOA for formaldehyde’s effect on nasal cancer risk was concluded to involve mutagenicity, the unit risk estimate was adjusted for assumed increased early-life susceptibility. While, ideally, estimates for NPC and myeloid leukemia (and sinonasal cancer, were sufficient quantitative data available) would be combined to derive the inhalation unit risk (IUR) for formaldehyde^59^, there is considerable scientific uncertainty in the data used to estimate a unit risk for myeloid leukemia. Therefore, a unit risk estimate for myeloid leukemia is not included in the IUR.

### 5.2.1 Unit Risk Estimates for Nasal Cancer

A judgment that the evidence demonstrates that formaldehyde inhalation causes NPC cancer was based on robust human evidence of increased risk in groups exposed to occupational formaldehyde levels, and robust animal evidence of nasal cancers in rats and mice that exhibits steeply increasing incidence at high formaldehyde levels. Strong mechanistic support is provided across species (primarily rats, but also mice, monkeys, and humans), including genotoxicity (sometimes at low formaldehyde levels in rats), epithelial damage or remodeling, and cellular proliferation that are consistent with neoplastic development in a regional, temporal, and dose-related fashion.

EPA’s standard approach for deriving an inhalation unit risk (IUR) estimate using results from epidemiology studies involves using a regression coefficient that describes the relationship between increases in cancer risk and increases in cumulative exposure, and estimating a (upper-bound) lifetime extra risk-per-unit exposure concentration through a life-table analysis. Cumulative exposure, which incorporates both average concentration and the duration of time over which exposure occurred, is generally the preferred metric for quantitative estimates of lifetime risk from environmental exposure to carcinogens, and thus cumulative exposure was chosen as the exposure metric for calculations in this assessment. The “true” exposure metric best describing the biologically relevant delivered dose of formaldehyde is unknown. Few epidemiological studies presented dose-response analyses based on cumulative measures of formaldehyde concentration that could support the derivation of unit risk estimates. A unit risk estimate was derived based on dose-response modeling of mortality and cumulative formaldehyde exposure for nasopharyngeal cancer (NPC) in a human occupational cohort. Upper respiratory tract (URT) cancer risk was also extrapolated from the incidence of nasal squamous cell carcinoma (SCC) in experimental studies on F344 rats. Results from several approaches used to model these data are evaluated and compared, including biologically based dose-response (BBDR) modeling, statistical time-to-tumor modeling, and statistical benchmark dose modeling using data on DNA-protein crosslinks (DPXs) and formaldehyde flux as dose measures. Additional analyses and comparisons were conducted based on mechanistic hypotheses, including derivation of RfCs based solely on estimates of cell proliferation (i.e., one contributing MOA to formaldehyde exposure-induced nasal cancers; see MOA discussion in Section 3.2.5), and assessing impacts of endogenous formaldehyde concentration on dosimetric estimates.

#### Derivation of Nasopharyngeal Cancer Unit Risk Estimates Based on Human Data

##### Choice of epidemiology studies

While several studies of cancer in workers exposed to formaldehyde evaluated exposure-response relationships, most reported the results of categorical analyses, only a few reported risk estimates in relation to changes in formaldehyde concentration or cumulative exposure rather than duration of exposure, TSFE, probability of exposure, or exposure intensity score, measures which are not generally adequate for the derivation of cancer unit risk estimates. One high confidence result from Beane Freeman et al. (2013) presented results of the follow-up of the large National Cancer Institute (NCI) retrospective cohort mortality study [originally described by Blair et al. (1986)] of workers at 10 U.S. plants producing or using formaldehyde. Six medium confidence study reported results but did not have critical information on slope parameters that could be used to derive an IUR. The available high and medium confidence epidemiology studies of NPC cancer were evaluated for use in deriving a cancer unit risk estimate (see Table 5-26).

Table 5-26 Eligible epidemiology studies for POD derivation and rationale for decisions to not select specific studies for nasal cancer

Study, Endpoint | Dose-Response Considerations (see Section 2.7) | | | | | Decision
Study, Endpoint | Study Evaluation | Population or Subjects | Exposure | Outcome Measure(s) | Result(s) Utility | Decision
(Beane Freeman et al., 2013) Nasopharyngeal cancer | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F); [+] Participation rate of cases (96%) and controls (94%) | [+] 2000 air samples; [+] Individuallevel continuous exposure; [+] Wide range (0.0–107.4 ppmyears); [+] Blinded to outcome | [+] Mortality: underlying cause from death certificates ICD-8: 147 | [n] N = 11 cases among 25,619 workers; [+] Poisson regression with slope parameters provided by Beane Freeman (Jinot and Beane-Freeman, 2014) | POD derived, no notable limitations.
(Hauptmann et al., 2009); Nasopharyngeal cancer | [n] Medium confidence; [-] Possible information bias (low sensitivity); [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F) | [+] Individual level, based on lifetime work practices and exposures to formaldehyde using a predictive model based on exposureassessment data; [+] Low levels and wide range (0 to >9253 pp-hrs; level = 0.01 ppm | [+] Mortality: underlying cause from death certificates ICD-8: 147 | Critical concern:; [-] N = 4 cases out of 6,808 embalmers and funeral directors; N=2 exposed cases; [--] Analysis limited to ever/never exposed | No POD derived. Critical concern with results utility for doseresponse analysis.
(Hildesheim et al., 2001); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | [+] N=375 cases with N = 74 exposed; [+] Logistic regression analysis | No POD derived. Critical concern with results utility for doseresponse analysis.
(Hildesheim et al., 2001); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | Critical concern: [--] No regression analyses by continuous exposure | No POD derived. Critical concern with results utility for doseresponse analysis.
(Vaughan et al., 2000); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | [+] N = 196 cases with n = 79 exposed; [+] Logistic regression analysis | No POD derived. Critical concern with results utility for doseresponse analysis.
(Vaughan et al., 2000); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | Critical concern:; [--] No regression analyses by continuous exposure | No POD derived. Critical concern with results utility for doseresponse analysis.
(West et al., 1993); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias unlikely; [n] Negative confounding possible by controlling for mosquito coils | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | [+] N = 104 cases with n = 27 exposed; [+] Logistic regression analysis | No POD derived. Critical concern with results utility for doseresponse analysis.
(West et al., 1993); Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias unlikely; [n] Negative confounding possible by controlling for mosquito coils | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | Critical concern:; [--] No regression analyses by continuous exposure | No POD derived. Critical concern with results utility for doseresponse analysis.
(Roush et al., 1987b) Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | [+] N = 173 cases with n = 21 exposed; [+] Logistic regression analysis | No POD derived. Critical concern with results utility for doseresponse analysis.
(Roush et al., 1987b) Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | Critical concern:; [--] No regression analyses by continuous exposure | No POD derived. Critical concern with results utility for doseresponse analysis.
(Olsen et al., 1984) Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | [+] N = 266 cases; [+] Matched case-control analysis analyses by continuous exposure | No POD derived. Critical concern with results utility for doseresponse analysis.
(Olsen et al., 1984) Nasopharyngeal cancer | [n] Medium confidence; [+] Selection bias and confounding unlikely | N/A | Some concern:; [-] Possible information bias (low sensitivity) | N/A | Critical concern:; [--] No regression | No POD derived. Critical concern with results utility for doseresponse analysis.

Thus, the quantitative analyses presented in this Toxicological Review are based on the NPC (Beane Freeman et al., 2013) results from the latest follow-up of the NCI cohort of industrial workers exposed to formaldehyde. The NCI cohort study is the largest of the three independent industrial worker cohort studies [the other two being Meyers et al. (2013) and Coggon et al. (2014)] and, more importantly, it is the only one with sufficient individual exposure data for exposure-response modeling. In addition, the NCI study is the only one of the three studies that used internal comparisons rather than standardized mortality ratios (SMRs), thus minimizing the potential impact of the healthy worker effect by addressing unmeasured confounding, which can bias effect estimates.

The NCI cohort consists of 25,619 workers (88% male) employed in any of the 10 plants prior to 1966. The most recent follow-up, based on 998,239 person-years of observation (through 2004) reported a total of 13,951 deaths (Beane Freeman et al., 2013). Beane Freeman et al. (2013) analyzed 10 deaths from NPC as well as deaths from other solid tumors. Some demographic details about the cohort are summarized in Table 5-27.

Table 5-27 Demographic details about the NCI industrial workers cohort^a^

Factor | Quantity
Number of workers | 25,619
Person-years of follow-up | 998,239
Percentage male | 87.8%
Percentage white | 92.7%
Percentage hourly workers | 78.5%
Median duration of follow-up | 42 years
Median (range) length of employment | 2.6 years (<1 day–47.7 years)
Number of deaths | 13,951
Number of cancer deaths | 3,703

a Follow-up through December 31, 2004 (Beane Freeman et al., 2013).

A detailed exposure assessment was conducted for each worker in the NCI cohort, based on exposure estimates for different jobs held and tasks performed (Stewart et al., 1986). Exposure estimates were made using several different metrics—peak exposure, average intensity, cumulative exposure, and duration of exposure. Respirator use and exposures to formaldehyde-containing particulates and other chemicals were also considered. Some exposure details about the cohort are summarized in Table 5-28.

Table 5-28 Exposure details about the NCI industrial workers cohort^a^

Factor | Quantity
Percentage workers never exposed | 10.5%
Median (range) formaldehyde TWA8 for exposed workers | 0.3 (0.01–4.3) ppm
Median (range) cumulative exposure for exposed workers | 0.6 (0.0–107.4) ppm × years
Number of workers who experienced peak exposures ≥4 ppm | 6,255

a Follow-up through December 31, 2004 (Beane Freeman et al., 2013).

For NPC, RR estimates were increased in the highest exposure category for each of the exposure metrics (Beane Freeman et al., 2013), although these increases were generally not statistically significant, given the small number of deaths involved. A statistically significant trend was observed only for the peak exposure metric and only among the exposed person-years [two of the 10 deaths from this rare cancer were in the unexposed workers (Beane Freeman et al., 2013)]. The (log-linear) trend for cumulative exposure (as a continuous variable) approached statistical significance (p = 0.06 among exposed person-years only and p = 0.07 among all person-years). With respect to the other solid cancers of interest, while Beane Freeman et al. (2013) reported results for cancers of the nose and nasal sinus, there were just five deaths for that endpoint. Marsh et al. (2002) reported some exposure-response results from their case-control study of all pharyngeal cancers in one of the industrial plants studied by the NCI, but they did not observe positive trends for cumulative or average exposure.

##### Exposure assessment and choice of exposure metric from the National Cancer Institute cohort

A detailed exposure assessment was conducted for the NCI cohort of industrial workers exposed to formaldehyde, and quantitative exposure estimates were generated for each worker (Stewart et al., 1986). Formaldehyde exposure estimates, including TWA8 concentration and categories of peak concentrations, were derived for each job, work area, and calendar year combination. A peak was defined as a short-duration exposure (typically <15 minutes) above the TWA, which could be related to either routine or nonroutine tasks (Beane Freeman et al., 2009). The frequency of peak exposures was also estimated, but these estimates were based on assumptions made by the assessors rather than direct measures or observations, making this metric highly uncertain. Cumulative exposures (in ppm × years) were estimated by multiplying the time a worker spent in a specific job by the TWA exposure for that job and summing over all the jobs held by the worker. Duration was the total time spent in jobs with formaldehyde exposure, and average intensity was the ratio of cumulative exposure to duration. Formaldehyde exposures after 1980 were not taken into account in the follow-up study, but this was considered to have a generally minimal impact on the results (Beane Freeman et al., 2013).

Some of the strongest exposure-response relationships in the NCI cohort studies (Beane Freeman et al., 2013) (e.g., for NPC) were observed for the peak exposure metric. It is not clear how to extrapolate RR estimates based on peak exposure estimates to meaningful estimates of lifetime extra risk of cancer from continuous exposure to low environmental levels. In addition, peak exposure level is a more subjective measure than the other metrics, it is not based on formaldehyde concentration measurements, and it is a categorical rather than continuous measure. Individual workers were assigned to peak exposure level categories based on their work histories and a matrix of job-, work area-, and calendar time-specific TWA8 formaldehyde measurements. Historical sampling records and sampling conducted by the investigators contributed to the development of this matrix. If a short-term (<15 minute) excursion above the TWA8 concentration for a job was observed, or expected based on industrial hygiene expertise, then that job was assigned to a peak exposure category: none, >0 to <0.5 ppm (>0 to 0.62 mg/m^3^), 0.5 to <2.0 ppm (0.62 to <2.46 mg/m^3^), 2.0 to <4.0 ppm (2.46 to 4.92 mg/m^3^), or ≥4.0 ppm (≥4.92 mg/m^3^). Individual workers may have experienced these peak concentrations rarely, intermittently, or routinely, and in jobs they held for a long time or only briefly. At a given time point, a worker’s peak exposure estimate is the highest peak exposure category ever attained by the worker. As such, this exposure metric is not interpretable in terms of a lifetime exposure risk.

Similarly, the average exposure metric is not a measure of long-term exposure for chronic effects because it does not account for duration of exposure (e.g., exposure to a given exposure level for 1 year conveys the same amount of risk as exposure to the same level for 70 years). Likewise, duration of exposure does not account for the level of exposure and is not a useful metric for the calculation of risk estimates as a function of exposure level, such as the cancer unit risk estimate.

Cumulative exposure, which incorporates both average concentration and the duration of time over which exposure occurred, is generally the preferred metric for quantitative risk assessment of lifetime risk from environmental exposure to carcinogens, and cumulative exposure was chosen as the exposure metric for the risk estimate calculations for the cancer endpoints in this assessment. The “true” exposure metric best describing the biologically relevant delivered dose of formaldehyde is unknown.

##### Dose-response modeling of the National Cancer Institute cohort

The results of the internal analyses (i.e., comparing exposed workers to an internal referent group of other workers in the cohort) of Beane Freeman et al. (2013) for NPC using the cumulative exposure metric, with comparisons to the results using the peak exposure and average intensity metrics, are presented in Table 5-29. The relative risks (RRs; in this case, rate ratios) were estimated using log-linear Poisson regression models stratified by calendar year, age (in 5-year intervals), sex, and race (black/white) and adjusted for pay category (salary/wage). As shown by Callas et al. (1998), when age is well characterized and adjusted for, as it was in the Beane Freeman et al. (2013) study, the Poisson regression and Cox proportional hazards models yield essentially the same results. Beane Freeman et al. (2013) used a 15-year lag interval in estimating exposures to account for a latency period for the development of solid cancers, including NPCs. Lag intervals of 2–20 years were evaluated, and changing the interval had little impact on the RR estimates; thus, the interval of 15 years that was used in the previous follow-up analyses (Hauptmann et al., 2004) was retained. For all cancer types, the NCI investigators used the low-exposure category as the reference category to “minimize the impact of any unmeasured confounding variables since nonexposed workers may differ from exposed workers with respect to socioeconomic characteristics” (Hauptmann et al., 2004). Table 5-29 also presents the p-value for the (log-linear) trend of risk changing with exposure level for all workers and for only those workers exposed to formaldehyde. The strongest exposure-response relationship for NPC is observed for the peak exposure metric among exposed workers.

The log-linear trend analyses for the cumulative exposure metric approach statistical significance (p-trend = 0.07 for all person-years; p-trend = 0.06 for exposed person-years only). The fact that the two-sided p-values are not strictly <0.05 is not critical here, given that the hazard for NPC was established a priori in Chapter 1. The nonexposed person-years were included in the primary cancer risk analyses to use all the available exposure-response data. Furthermore, the data were stratified by pay category, which provided at least partial adjustment for socioeconomic characteristics. Final results for the exposed person-years only are also presented for comparison.

The log-linear trend tests conducted by Beane Freeman et al. (2013) used exposure as a continuous variable (except for peak exposure, for which categorical ranks were used) (general model form: RR = e^βX^, where β represents the regression coefficient and X is exposure). Dr. Beane Freeman provided EPA with the β estimates (and their standard errors) from the trend tests for NPC and the cumulative exposure metric for all person-years and for exposed person-years only (personal communication to EPA from Laura Beane Freeman, NCI, to Jennifer Jinot, EPA, February 22, 2013). These estimates are presented in Table 5-29.

Table 5-29 Relative risk estimates for mortality from nasopharyngeal malignancies (ICD-8 code 147) by level of formaldehyde exposure for different exposure metrics

Rate ratio (number of deaths) | | | | p-Trend
Rate ratio (number of deaths) | | | | All person-years^a^ | Exposed personyears^b^
Peak exposure (ppm)
0 | >0 to <2.0^c^ | 2.0 to <4.0 | ≥4.0
4.39 (2) | 1.0 (1) | − (0) | 7.66 (7) | 0.10 | 0.005
Average intensity (ppm)
0 | >0 to <0.5^c^ | 0.5 to <1.0 | ≥1.0
6.79 (2) | 1.0 (1) | 2.44 (1) | 11.54 (6) | 0.16 | 0.09
Cumulative exposure (ppm × years)
0 | >0 to <1.5^c^ | 1.5 to <5.5 | ≥5.5
1.87 (2) | 1.0 (4) | 0.86 (1) | 2.94 (3) | 0.07 | 0.06

a Likelihood ratio test (1 degree of freedom) of zero slope for formaldehyde exposure (continuous variable, except for peak exposure metric) among all (nonexposed and exposed) person-years.

b Likelihood ratio test (1 degree of freedom) of zero slope for formaldehyde exposure (continuous variable, except for peak exposure metric) among exposed person-years only.

c Reference category for all categories with the same exposure metric.

Source: Beane Freeman et al. (2013).

Table 5-30 Regression coefficients from NCI log-linear trend test models for NPC mortality from cumulative exposure to formaldehyde^a^

Person-years | β (per ppm × year) | Standard error (per ppm × year)
All | 0.04311 | 0.01865
Exposed only | 0.0439 | 0.01852

a Models stratified by calendar year, age, sex, and race and adjusted for pay category; cumulative exposures calculated using a 15-year lag interval.

Source: Personal communication to EPA from Laura Beane Freeman to Jennifer Jinot (February 22, 2013).

###### Prediction of lifetime extra risk of nasopharyngeal cancer mortality

The regression coefficients presented in Table 5-30 were used to predict the extra risk of NPC mortality from environmental exposure to formaldehyde.

Extra risk = ( R_x_ − R_o_ ) ÷ ( 1 − R_o_ ) , (Eq. 5-3)

where R_x_ is the lifetime risk in the exposed population and R_o_ is the lifetime risk in an unexposed population (i.e., the background risk). Extra risk estimates were calculated using the β regression coefficients and a life-table program that accounts for competing causes of death.^60^ U.S. age-specific 2010 all-cause mortality rates and 2000–2010^61^ NPC (ICD-10 C11.0-C11.9) mortality rates for all race and sex groups combined^62^ were used to specify the all-cause and cause-specific background mortality rates in the life-table program. Risks were computed up to age 85 because cause-specific mortality (and incidence) rates for ages above 85 years are less reliable. Conversions between occupational formaldehyde exposures and continuous environmental exposures were made to account for differences in the number of days exposed per year (240 versus 365) and in the amount of air inhaled per day (10 versus 20 m^3^). An adjustment was also made for the 15-year lag period. The reported standard errors for the regression coefficients were used to compute the one-sided 95% upper confidence limits (UCLs) for the extra risks based on a normal approximation.

Point estimates and one-sided 95% UCLs for the extra risk of NPC mortality associated with varying levels of continuous exposure to formaldehyde are presented in Table 5-31. The model predicts extra risk estimates that are fairly linear for exposures below about 0.001 to 0.01 ppm but not for exposures above 0.01 ppm.

Table 5-31 Extra risk estimates for nasopharyngeal cancer mortality from various levels of continuous exposure to formaldehyde

Exposure concentration (ppm) | Extra risk | 95% UCL on extra risk
0.0001 | 1.24 × 10^–7^ | 2.12 × 10^–7^
0.001 | 1.24 × 10^–6^ | 2.13 × 10^–6^
0.01 | 1.28 × 10^–5^ | 2.25 × 10^–5^
0.1 | 1.79 × 10^–4^ | 4.12 × 10^–4^
1 | 2.67 × 10^–1^ | 8.74 × 10^–1^
10 | 9.83 × 10^–1^ | 9.87 × 10^–1^

Consistent with EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), the same data and methodology were also used to estimate the exposure level (effective concentration [ECx]) and the associated (one-sided) 95% lower confidence limit (LECx) corresponding to an extra risk of 0.05% (x = 0.0005). Although EPA guidelines emphasize the use of exposure levels associated with a 10% extra risk level for the POD for low-dose extrapolation, that would not be appropriate in this instance. A 10% extra risk level is very high for responses generally observed in epidemiology studies; thus, a 1% extra risk level is typically used for epidemiological data to avoid upward extrapolation. However, NPC has a very low background mortality rate (e.g., lifetime background risk is about 0.00019); therefore, even a 1% extra risk (i.e., 0.01) would be a large increase relative to the background risk. This is consistent with the fact that, even with a large cohort followed for a long time, only 10 NPC deaths were observed in the NCI follow-up through 2004.^63^ The 1% level of risk is associated with RR estimates that are substantially higher than those observed in the epidemiology study. Based on the life-table program, the RR estimate for an extra risk of 1% for NPC mortality is 53, an upward extrapolation. Even 0.1% yields an RR estimate on the high end of the observable range of the epidemiology study (RR = 6.2). A 0.05% extra risk level yields an RR estimate of 3.6, which better corresponds to the RRs in the range of the data. Thus, 0.05% extra risk was selected for determination of the POD, and, consistent with EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), the LEC value corresponding to that risk level was used as the POD.

Based on a detailed analysis conducted according to EPA’s cancer MOA framework (U.S. EPA, 2005a), it was concluded that two primary MOAs contribute to nasal cancers caused by formaldehyde inhalation exposure, namely mutagenicity and cytotoxicity-induced regenerative proliferation. Overall, there is strong and consistent evidence for both MOAs (see Section 3.2.5 for details). The data are insufficient to conclude that mutagenicity does not contribute at low exposure levels. In fact, multiple well-conducted studies demonstrate effects associated with mutagenicity (e.g., chromosomal changes) at exposure levels well below those causing cellular cytotoxicity, which is incompatible with a theory of carcinogenesis based solely upon exceedance of a cytotoxicity-based threshold. In accordance with the EPA cancer guidelines (U.S. EPA, 2005a, b), given the strong evidence for mutagenicity as a contributing MOA and the evidence-based understanding that mutagens can give rise to cancers with an apparently low-dose linear response, a linear low-dose extrapolation was performed. The EC_0005_, LEC_0005_, and IUR estimates for NPC mortality are presented in Table 5-32.

Table 5-32 EC_0005_, LEC_0005_, and unit risk estimates for nasopharyngeal cancer mortality from formaldehyde exposure based on the Beane Freeman et al.(2013) log-linear trend analyses for cumulative exposure

Person-years | EC_0005_ (ppm) | LEC_0005_ (ppm) | Unit risk^a^ (per ppm) | Unit risk (per mg/m^3^)
All | 0.191 | 0.112 | 4.5 × 10^–3^ | 3.7 × 10^–3^
Exposed only | 0.187 | 0.111 | 4.5 × 10^–3^ | 3.7 × 10^–3^

a Unit risk = 0.0005/LEC_0005_.

###### Prediction of lifetime extra risk of nasopharyngeal cancer incidence

EPA cancer risk estimates are typically derived to represent a plausible upper bound on increased risk of cancer incidence, as from experimental animal incidence data. Cancer data from epidemiology studies are more often mortality data, as is the case in the NCI study. For cancers with low survival rates, mortality-based estimates are reasonable approximations of cancer incidence risk. However, for NPC, the survival rate is substantial (51% at 5 years in the 1990s in the United States, according to Lee and Ko (2005) and incidence-based risks are preferred because EPA is concerned with cancer occurrence, not just cancer mortality.

Therefore, an additional calculation was done using the same regression coefficients provided by Dr. Beane Freeman (see Table 5-30) but with age-specific NPC incidence rates from NCI’s Surveillance, Epidemiology, and End Results (SEER) Program in place of the NPC mortality rates in the life-table program. SEER collects cancer incidence data from a variety of geographical areas in the United States. The incidence data used here are from SEER-18, a registry covering about 27.8% of the U.S. population, which was the most current SEER registry at the time this analysis was done. SEER-18 age-specific background incidence rates for NPC (ICD-10 C11.0-C11.9) for 2000–2010 were obtained from the SEER public-use database (www.seer.cancer.gov) using NCI’s SEER*Stat software (www.seer.cancer.gov/seerstat). The incidence-based calculation relies on the reasonable assumptions that NPC incidence and mortality have the same exposure-response relationship for formaldehyde exposure and that the incidence data are for first occurrences of NPC or that relapses provide a negligible contribution. The calculation, as presented in the life-table spreadsheet in Appendix D.2.1, also takes advantage of the fact that NPC incidence rates are negligible compared with the all-cause mortality rates and thus no special adjustment to the population at risk to account for live individuals who have been diagnosed with NPC is necessary.

The resulting EC_0005_, LEC_0005_, and IUR estimates for NPC incidence are presented in Table 5-33. The unit risk estimate for cancer incidence is two-fold higher than the corresponding mortality-based estimate, for all person-years, reflecting the high survival rates for NPC.

Table 5-33 EC_0005_, LEC_0005_, and unit risk estimates for nasopharyngeal cancer incidence from formaldehyde exposure based on the Beane Freeman et al.(2013) log-linear trend analyses for cumulative exposure

Person-years | EC_0005_ (ppm) | LEC_0005_ (ppm) | Unit risk^a^ (per ppm) | Unit risk (per mg/m^3^)
All | 0.0942 | 0.0550 | 9.1 × 10^–3^ | 7.4 × 10^–3^
Exposed only | 0.0925 | 0.0546 | 9.2 × 10^–3^ | 7.5 × 10^–3^

a Unit risk = 0.0005/LEC_0005_.

The selected estimate for the cancer unit risk for NPC, prior to any age adjustments is the estimate of 9.1 × 10^−3^ per ppm (7.4 × 10^−3^ per mg/m^3^) derived using incidence rates for the cause-specific background rates, for all person-years. The results from the exposed person-years are essentially identical.

Because NPC is a rare cancer in the United States, with a relatively low number of cases occurring per year, a rough calculation was done to ensure that the unit risk estimate derived for NPC incidence is not implausible in comparison to actual case numbers. For example, assuming an average constant lifetime formaldehyde exposure level of 5 ppb for the U.S. population, the IUR estimate for NPC equates to a lifetime extra risk estimate of 4.6 × 10^−5^. Assuming an average lifetime of 75 years (this is not EPA’s default average lifetime of 70 years but rather a value more representative of actual demographic data) and a U.S. population of 300,000,000, this lifetime extra risk estimate suggests a crude upper-bound estimate of 180 incident cases of NPC attributable to formaldehyde exposure per year. Alternatively, assuming an average constant lifetime formaldehyde exposure level of 20 ppb, the calculation suggests a crude upper-bound estimate of 730 incident cases of NPC per year. Both upper-bound estimates, using different assumed lifetime exposure levels, are well below the estimated 2,300 total incident NPC cases per year calculated from the SEER NPC incidence rate of 0.75/100,000.^64,65^

#### Derivation of Nasal Cancer Unit Risk Estimates Based on Squamous Cell Carcinoma in the Respiratory Tract Using Animal Data

In this section, dose-response analyses of cancer risk based on nasal tumor data from laboratory rodent bioassays are presented. The Agency takes the position that human data, if adequate data are available, provide a more appropriate basis for estimating human cancer risk than do rodent data (U.S. EPA, 2005a), primarily because uncertainties in extrapolating quantitative risks from rodents to humans are avoided; therefore, the epidemiology-derived estimates presented in the previous section are the selected unit risk estimates for nasal cancers.

Nonetheless, it is useful to compare human health risk estimates from available epidemiology data with estimates extrapolated from animal studies. Furthermore, a large body of mechanistic data on cell replication, DPX and DNA monoadduct formation, and dosimetry modeling of formaldehyde flux to local tissue exist for formaldehyde that can potentially inform the shape of the dose-response curve. This information, as well as data on the incidence of hyperplasia, facilitates the interpretation and extrapolation of nasal squamous cell carcinoma (SCC) incidence results from rodent bioassays within the context of formaldehyde’s reactivity and MOAs. The estimates derived from animal data incorporate this information into the modeling.

##### Choice of Animal Studies

The available high and medium confidence animal studies of nasal cancers were evaluated for use in deriving a cancer unit risk estimate (see Table 5-34). As was the case for hazard identification (see Section 3.2.5), studies of subchronic or shorter duration without long-term follow up to allow for the development of cancers were not considered.

Table 5-34 Eligible experimental animal studies for POD derivation and rationale for decisions to not select specific studies for nasal cancers

Study, species | Dose-response considerations (see Section 2.7) | | | | | Decision
Study, species | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Rat Studies
Monticello et al. (1996); Rats: F344 (M) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Males only | [+] 2-year exposure; [+] Broad exposure range (0.85 to 18.4mg/m^3^) | [+] 6 nasal cross sections; [n] Lack of blinding for tumor analyses not a significant limitation | [+] Large N (N = 90 - 147) | POD derived.; Concern noted regarding testing of males only.
Woutersen et al. (1989); Rats: Wistar (M) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Males only; [-] strain is less sensitive than other strains | [+] > 2-year exposure; [+] Broad exposure range (0.1 to 12.1 mg/m^3^) | [+] 6 nasal cross sections; [n] Lack of blinding for tumor analyses not a significant limitation | Some concern:; [-] Small N for detecting rare cancers (N = 32) | No POD derived. Study design more limited than others due to use of small N and males only.
Sellakumar et al. (1985); Rats: Sprague Dawley (M) | [+] High confidence; [n] Adequate exposure quality | Some concern:; [-] Males only | Critical concern:; [--] Single, high exposure (18.2 mg/m^3^) | [+] Multiple (interpreted as ≥ 5 based on study description) sections of the head (including nasal cavity), lung, trachea, and larynx; [n] Lack of blinding for tumor analyses not a significant limitation | [+] N = 99-100 | No POD derived.; Critical exposure concern.
Kerns et al. (1983); Rats: F344 (M+F) Related studies: (Battelle, 1981, 1982); [interim findings presented in Swenberg et al. (1980b)] | [+] High confidence; [+] Good exposure quality | Some concern:; [-] viral infection at weeks 52−53 caused transiently decreased body weight not expected to affect the cancer data (see Section 3.2.5). | [+] 2-year exposure (with follow-up to 30 months) | [+] 5 sections of nasal turbinates (Levels I−V) at all interim sacrifices and at study end [n] Lack of blinding for tumor analyses not a significant limitation. | [+] Large N (N = 119 - 121) [n] Limited reporting of dysplasia findings | POD derived.; Concern noted regarding transient viral infection.
Kamata et al. (1997); Rats: F344 (M) | [n] Medium confidence; [n] Adequate exposure quality | Some concern:; [-] Males only | [+] > 2-year exposure (28months); [+] Broad exposure range (0.40 to 18.3 mg/m^3^) | [+] Nasal region (sections from 5 anatomical levels) and trachea; [n] Lack of blinding for tumor analyses not a significant limitation. | Some concern:; [-] Small N for detecting rare cancers (N = 32) | No POD derived. Study design more limited than others due to use of formalin, small N, and males only.
Kamata et al. (1997); Rats: F344 (M) | [n] Medium confidence; [n] Adequate exposure quality | Some concern:; [-] Males only | Some concern:; [-] Use of formalin as test article (even with a methanol control group) introduces some quantitative uncertainty. | [+] Nasal region (sections from 5 anatomical levels) and trachea; [n] Lack of blinding for tumor analyses not a significant limitation. | Some concern:; [-] Small N for detecting rare cancers (N = 32) | No POD derived. Study design more limited than others due to use of formalin, small N, and males only.
Holmstrom et al. (1989b); Rats: Sprague Dawley (F) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Females only [-] Some health concerns noted | Critical concern:; [--] Single, high exposure (15.3 mg/m^3^) | [+] 5 sections of the nose, and the lungs; [+] slides blinded | Critical concern:; [-] Very small N for detecting rare cancers (N = 15-16) | No POD derived. Critical exposure and sample size concerns.
Appelman et al. (1988); Rats: SPF Wistar (M) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Males only [-] strain is less sensitive than other strains | [+] Broad exposure range (0.12 to 12.1 mg/m^3^) | [+] Nose (6 standard cross levels), larynx, trachea, and lungs; [n] Lack of blinding for tumor analyses not a significant limitation | Critical concern:; [--] Very small N for detecting rare cancers (N = 10) | No POD derived. Critical exposure and sample size concerns.
Appelman et al. (1988); Rats: SPF Wistar (M) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Males only [-] strain is less sensitive than other strains | Critical concern:; [--] Short duration for nasal cancers to develop (1 year) with no follow up | [+] Nose (6 standard cross levels), larynx, trachea, and lungs; [n] Lack of blinding for tumor analyses not a significant limitation | Critical concern:; [--] Very small N for detecting rare cancers (N = 10) | No POD derived. Critical exposure and sample size concerns.
Woutersen et al. (1989); Rats: Wistar (M) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Males only [-] strain is less sensitive than other strains | [+] Broad exposure range (0.1 to 11.3 mg/m^3^) | [+] 6 nasal cross sections; [n] Lack of blinding for tumor analyses not a significant limitation. | Some concern:; [-] Small N for detecting rare cancers (N = 30) | No POD derived. Critical exposure concern.
Woutersen et al. (1989); Rats: Wistar (M) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Males only [-] strain is less sensitive than other strains | Critical concern:; [--] 3-month exposure (note: with long-term follow up) | [+] 6 nasal cross sections; [n] Lack of blinding for tumor analyses not a significant limitation. | Some concern:; [-] Small N for detecting rare cancers (N = 30) | No POD derived. Critical exposure concern.
Feron et al. (1988); Rats: Wistar (M) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Males only [-] strain is less sensitive than other strains | Critical concern:; [--] 13-week exposure (note: with long-term follow up); [--] High exposure levels only (> 11 mg/m^3^) | [+] 6 standard cross levels of the nose.; [n] Lack of blinding for tumor analyses not a significant limitation. | [n] N = 45 | No POD derived. Critical exposure concerns.
Feron et al. (1988); Rats: Wistar (M) | | | | | Some concern:; [-] Limited reporting on timing of tumor development to inform quantitative analyses.
Mouse Studies
Kerns et al. (1983); Mice: B6C3F1 (M+F); Related studies: Battelle (1981, 1982) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Survival to 18 mo. < 33% in exposed males; [-] mice are less sensitive than rats^b^ | [+] 2-year exposure (with follow-up to 30 months); [+] Broad exposure range (2.5 – 17.6 mg/m^3^) | [n] Lack of blinding for tumor analyses not a significant limitation. | [+] Large N (N = 119-121); [n] Limited reporting of dysplasia findings | No POD derived. Results less useful than others due to concerns regarding survival, sampling, and reporting.
Kerns et al. (1983); Mice: B6C3F1 (M+F); Related studies: Battelle (1981, 1982) | [+] High confidence; [+] Good exposure quality | Some concern:; [-] Survival to 18 mo. < 33% in exposed males; [-] mice are less sensitive than rats^b^ | [+] 2-year exposure (with follow-up to 30 months); [+] Broad exposure range (2.5 – 17.6 mg/m^3^) | Some concern:; [-] only 3 nasal sections evaluated | [+] Large N (N = 119-121); [n] Limited reporting of dysplasia findings | No POD derived. Results less useful than others due to concerns regarding survival, sampling, and reporting.
Other species
Dalbey (1982); Hamsters: Syrian golden (M) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Males only; [-] hamsters are less sensitive than rats | Critical concern:; [--] Single, high exposure (12.3 mg/m^3^) | [n] Lack of blinding for tumor analyses not a significant limitation | [+] Large N = 132 controls and 88 exposed | No POD derived. Critical exposure concern.
Dalbey (1982); Hamsters: Syrian golden (M) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Males only; [-] hamsters are less sensitive than rats | Critical concern:; [--] Single, high exposure (12.3 mg/m^3^) | Some concern:; [-] Only two nasal sections, with sections of the larynx, trachea, and lungs | Some concern:; [-] multiple concerns noted regarding reporting (see Appendix B.3.9) | No POD derived. Critical exposure concern.

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.9 for details).

b Mice, and possibly other species, have a greater reflex bradypnea response to irritants than rats, which can result in a lower internal exposure at the same external formaldehyde concentrations (see Appendix C.2).

Section 3.2.5 provides the details of the long-term cancer bioassays of high and medium confidence in rats. The two largest studies (Kerns et al., 1983) and (Monticello et al., 1996) involved F344 rats with at least 230 animals and 90 animals, respectively, in each dose group and a well-defined spread of multiple dose groups. The Woutersen et al. (1989) study involved Wistar rats, and as discussed in the synthesis text, this strain is thought to be resistant to the formation of SCCs. The studies by (Holmstrom et al., 1989b) and (Sellakumar et al., 1985) were on SD rats and were single dose studies. The study by (Kamata et al., 1997) on F344 male rats had multiple doses but was limited by its small sample size and the use of formalin as the test article. While long term inhalation bioassays were conducted in mice and this species also develops nasal tumors after formaldehyde inhalation exposure, the available data indicate rats to be the most sensitive lab rodents, and the mouse dose response may not be the appropriate model because of the ability of mice to lower their inhalation rate in response to formaldehyde induced irritation. Therefore, EPA focused on the (Kerns et al., 1983) and (Monticello et al., 1996) bioassays for dose-response modeling of the animal nasal cancer data.

The following section describes the data and modeling approaches available; presents PODs from the considered models at benchmark response rates in the range of the available data; presents results from a biologically based model for extrapolation to human exposure scenarios; evaluates uncertainties in the dose-response models and discusses the use of any of the models for extrapolating below the POD, including implications for low-dose risk; and presents candidate IURs and RfCs derivable from the modeled PODs.

##### Animal nasal tumor incidence data

An increased incidence of nasal SCC was seen in two long-term bioassays using F344 rats (Monticello et al., 1996; Kerns et al., 1983). The dose-response data from these two studies were statistically evaluated for heterogeneity by combining the data and stratifying the analysis by study (see Appendix D.2.2). Model parameters for the two studies were found to be statistically equivalent (p-value> 0.05). Therefore, it was considered appropriate to combine these studies for greater power in dose-response analysis even though they were conducted 13 years apart. The pooled data (Table 5-35) provide a well-defined spread of concentrations and provide the most robust data among the various animal studies for analyses. The individual animal data from these studies, along with results from an additional 94 animals not previously examined in the Monticello et al. (1996) study, were provided to EPA by the Chemical Industry Institute of Toxicology (CIIT) which contracted or conducted the studies. In 2004, CIIT issued a memo to EPA that corrected errors in the original report for the (Kerns et al., 1983) study; the memo (Bermudez, 2004) is reproduced in the Appendix D.2.2. Table 5-35 shows only the grouped incidence from the two studies combined, the individual animal incidence data used in the assessment are tabulated in Appendix D.2.2.

Table 5-35 F344 rat nasal cancer data

Formaldehyde exposure levels | Incidence of SCC tumors | References
0, 0.7, 2.0, 6.01, 9.93, and 14.96 ppm (0, 0.86, 2.5, 7.4, 12.2, and 18.4 mg/m^3^) | 0/341, 0/107, 0/353, 3/343, 22/103, 162/386 | Monticello et al. (1996); Kerns et al. (1983); Bermudez (2004) (combined bioassays)

##### Mechanistic information

In addition, three types of mechanistic information are incorporated in some of the dose-response modeling. These include site-specific measurements of DNA-protein crosslinks (DPX) formed by formaldehyde in the F344 rat and rhesus monkey, site-specific measurements of changes in cell labeling induced by inhalation exposure to formaldehyde in the F344 rat, and estimates of formaldehyde flux to the nasal tissue derived using computational fluid dynamics modeling. The DPX estimates used in the dose-response modeling are derived from physiologically based pharmacokinetic (PBPK) models that have been developed based on the DPX data in Table 5-36 to calculate DPX levels as a function of local formaldehyde flux, and to predict DPX levels in the human.

##### Computational fluid dynamic modeling

The ability to use mechanistic data in dose-response modeling is further facilitated by the availability of computational fluid dynamic (CFD) modeling of airflow in the rat, monkey, and human respiratory passages. The CFD modeling is useful on multiple accounts.

Formaldehyde-induced squamous cell carcinomas (SCCs) and other lesions that occur in the rat and monkey nasal passages and in the monkey LRT are seen to be distributed in localized patterns that differ across species. The anatomy of the respiratory tract, in particular the nasal passages, and the pattern of airflow, show large regional differences across species (see Appendix A). On this basis, several authors have argued that regional dose would be the main determinant of interspecies differences in tumor incidence for a highly reactive and water soluble chemical such as formaldehyde (Morgan et al., 1991; Monticello and Morgan, 1994; Monticello et al., 1996; Bogdanffy et al., 1999), thus motivating the use of modeling local formaldehyde flux in the nasal region of each species.

Kimbell et al. (1993), Kepler et al. (1998), and Subramaniam et al. (1998) developed anatomically realistic finite-element representations of the noses of F344 rats, rhesus monkeys, and humans, and used them in physical and computational models (Kimbell et al., 2001a; Kimbell et al., 2001b). The nasal dosimetry modeling by (Kimbell et al., 2001a; Kimbell et al., 2001b) was revised by Schroeter et al. (2014) to include air:tissue partitioning and air and tissue phase diffusivity; production of endogenous formaldehyde in the respiratory mucosa as a zero-order process; clearance of formaldehyde in the form of a saturable pathway for enzymatic metabolism, a first-order pathway for nonenzymatic reactions, and a pseudo first-order pathway to include its binding to DNA to form DPX.

This assessment uses dosimetry derived from (Kimbell et al., 2001a; Kimbell et al., 2001b) when extrapolating risk-related dose from the rat to the human (discussed in detail in Appendix C.1.12 and D.2.2), and estimates the impact on the point of departure of using an alternate dosimetry model developed by Schroeter et al. (2014). Furthermore, DPX levels and cell labeling data are characterized as a function of regional formaldehyde flux to further inform the interpretation of cancer incidence results. These are tabulated in Table 5-36 and used in the risk estimates from different dose-response methods presented in Table 5-37 (see Appendix D.2.2 for additional details).

Table-5-36 Dosimetric and mechanistic information supporting doseresponse assessment based on rat nasal tumors

Data or information | Formaldehyde exposure | Notes | Study references
FA dosimetry in anatomically realistic representations of the F344 rat and human nasal passages and in an idealized representation of the human lower respiratory tract | Inhaled concentrations of 0, 0.7, 2, 6, 10, or 15 ppm (0, 0.9, 2.5, 7.4, 12.3, or 18.5 mg/m^3^) at various steady-state inhalation rates | Fluid dynamic models of local FA flux to tissue. | Subramaniam et al. (2008); Overton et al. (2001); Kimbell et al. (1993); Kimbell et al. (1997b); Kimbell et al. (2001a); Kimbell et al. (2001b). See Appendix B.2
DPX^a^ in F344 rat (2 studies) and in rhesus monkey | Rat study 1 (1989): 0.3, 0.7, 2.0, 6.0, 10.0 ppm (0.4, 0.9, 2.5, 7.4, 12.3 mg/m^3^) for 6 hours. Rat study 2 (1994): 0.7, 2.0, 6.0, 15.0 ppm (0.9, 2.5, 7.4, 18.5 mg/m^3^) for 3 hours. DPX measured over whole nose in study 1, and over two regions (“low” and “high” tumor sites) in study 2. Monkey study: 0.7, 2.0, 6.0 ppm (0.9, 2.5, 7.4 mg/m^3^) for 6 hours | DPX lesions observed at all exposure concentrations (0.3 ppm–15 ppm/0.37 mg/m^3^–18.5 mg/m^3^). DPX tracheal and lung lesions in monkeys at 6.0 ppm (7.4 mg/m^3^). Data used in PBPK model for FA and DPX | Conolly et al. (2000); Casanova et al. (1989); Casanova et al. (1991); Casanova et al. (1994)
Cell labeling index^b^; F344 rats. Labeling study with two phases | 0, 0.7, 2, 6, 10, or 15 ppm (0, 0.9, 2.5, 7.4, 12.3, or 18.5 mg/m^3^). Phase 1 exposure duration: 1, 4, and 9 days and 6 weeks. Phase 2 exposure duration: 13, 26, 52, and 78 weeks | Phase 1 used injection labeling with a 2-hour pulse of tritiated thymidine; Phase 2 used osmotic mini pump tritiated thymidine labeling with a 120-hour release time | Phase 1: Monticello et al. (1991). Phase 2: Monticello et al. (1996); Data analyzed in Appendix B.

Abbreviations: FA = formaldehyde exposure; DPX = DNA-protein crosslink; PBPK = physiologically based pharmacokinetic.

a Note that these studies do not present DPX measurements on control animals.

b These data were used as input for modeling the nasal tumors observed in F344 rats and for benchmark modeling of cell proliferation as a precursor response by authors from the same laboratory as this study (Schlosser et al., 2003; Conolly et al., 2003). Many other studies (see below on “uncertainty in dose-response estimates”) inform the effect of formaldehyde on cell proliferation and are brought to bear upon the discussion of uncertainties in modeling the dose-response. However, Monticello et al. (1996) is the only study that followed long-term exposure to formaldehyde.

##### Dose-response modeling of nasal SCC incidence in the rat

The results discussed in this section and presented in Table 5-37 include multiple dose-response models of the observed pooled tumor incidence in F344 rats from the two studies (Monticello et al., 1996; Kerns et al., 1983). These results include those developed by EPA in this assessment as well as those developed earlier by Schlosser et al. (2003). Dose metrics derived from PBPK modeling of formaldehyde-induced DPX or from CFD modeling of formaldehyde flux to the nasal tissue are included in these approaches in addition to presenting a result based on the inhaled exposure concentration. The approaches include modeling the grouped incidence data, multistage Weibull modeling of the individual time-to-tumor data, and a biologically based clonal expansion model of cancer. Use of the biologically based modeling allowed the use of various data, including mechanistic information, in an integrated manner. Formaldehyde is a direct-acting mutagen, and DPXs serve as a surrogate marker for the tissue dose associated with this mutagenic potential. The individual tumor incidence data, flux estimates and number of cells organized by flux bins, and DPX concentrations used in the dose-response modeling are tabulated in Appendix D.2.2.

###### Modeling of the grouped incidence data

Schlosser et al. (2003) applied a Kaplan-Meier survival adjustment of the grouped incidence data. The best fit in Schlosser et al. (2003) was obtained with the polynomial and Weibull models for the tumor incidence data with a nonzero intercept (threshold) on the dose axis. Two sets of results from their work are presented in Table 5-37, one using formaldehyde flux to the nasal tissue and the other using DPX concentration as dose metrics to calculate benchmark levels and corresponding HECs. DPX as the dose metric was expressed as pmol of formaldehyde equivalents covalently bound to DNA per unit volume of nasal tissue. These calculations used CFD and PBPK models to calculate formaldehyde flux and DPX concentrations in the rat and human. The assumption in using DPX data to calculate the HEC was that lifetime exposure to the same DPX concentration for a given duration each day leads to equivalent risk across species. These were exposures that resulted in the same steady-state DPX concentrations as the weekly time-weighted averaged DPX values in rats at the rat benchmark exposure concentrations. See Schlosser et al. (2003) for further details.

###### Time-to-tumor modeling without using mechanistic data

Because higher exposures were associated with both earlier tumor occurrence and increased mortality in the rats, methods that can reflect the influence of competing risks and intercurrent mortality on site-specific tumor incidence rates are preferred. For this reason, EPA used the multistage Weibull time-to-tumor model (Portier and Bailer, 1989; Krewski et al., 1983), which (a) models the replicate animal data, (b) includes the exact time of observation of the tumors and therefore gives appropriate weight to the amount of time each animal was on study without a tumor, and (c) acknowledges earlier tumor incidence with increasing dose level. The dose-response analyses, estimation of parameters, and plots of model fits are detailed in Appendix D.2.2.

###### Biologically based dose-response modeling

Biologically based time-to-tumor dose-response (BBDR) model for modeling the formaldehyde-induced rat nasal tumors, and for extrapolating the rat nasal cancer risk to human exposure scenarios are available (Conolly et al., 2003, 2004; CIIT, 1999). These models consist of interfacing dosimetry models for formaldehyde and formaldehyde-induced DPX in the rat nasal passages (Kimbell et al., 2001a; Kimbell et al., 2001b; Conolly et al., 2000) with a two-stage clonal expansion (TSCE) model for predicting the probability of occurrence of nasal SCC. The term “BBDR modeling” is used here to collectively refer to various toxicokinetic and toxicodynamic dose-response modeling components.

The CIIT BBDR models as well as their possible variations explored by EPA were carefully evaluated. Predictions using these models for humans are found to be not robust at any exposure concentration. Accordingly, the clonal expansion modeling of the rat data is employed to derive multiple PODs and corresponding HECs but it is not used for extrapolating to human exposure scenarios. Unit risks derived by straight line extrapolation from a POD as well as candidate RfCs (cRfCs) derived from benchmark modeling of data on cell proliferation and basal hyperplasia observed in F344 rats and Wistar rats, respectively, are also presented, with the cRfC interpreted as the concentration below which nasal cancers arising from increased cell proliferation due to formaldehyde-induced cytotoxicity are unlikely to occur. The assessment presents arguments from the literature that protection against these putative precursor events is sufficient to prevent a cancer response. However, the proven genotoxicity and mutagenicity of the chemical and the observation of human cytogenetic effects in human occupational exposures provide strong support for preferring the linear extrapolation from the POD to the origin. Candidate unit risks based on a point of departure at the 0.005 extra risk are found to be comparable to that derived from analysis of the NCI occupational epidemiology data on nasopharyngeal cancers (NPCs).

The cancer modeling in the BBDR approach is based on an approximation of the Moolgavkar, Venzon, and Knudson stochastic TSCE model of cancer (Moolgavkar and Venzon, 1979; Moolgavkar and Knudson, 1981; Moolgavkar et al., 1988), which accounts for growth of a pool of normal cells, mutation of normal cells to initiated cells, clonal expansion of initiated cells, and mutation of initiated cells to fully malignant cells. The molecular dose associated with formaldehyde’s direct mutagenic action was represented in this approach by the DPX formed by formaldehyde. Exposure to inhaled formaldehyde induces dose-related changes in rates of cell division as inferred from cell labeling studies in the formaldehyde-exposed F344 rat. In turn, regenerative increases in cell proliferation increase the probability of errors in DNA replication. Formaldehyde-induced changes in cell replication and DPX concentrations, derived from the data indicated in Table 5-36, were considered a function of local formaldehyde flux (pmol/mm^2^-hour) to each region of nasal tissue as predicted by CFD modeling on anatomically accurate representations of the nasal passages of a single F344 rat (see Appendix C.1). The TSCE model was calibrated with the observed tumor incidence data to estimate various unknown parameters as indicated below. DPX tissue concentrations in Conolly et al. (2003) were calculated using a physiologically based pharmacokinetic model developed in Conolly et al. (2000).

Conolly et al. (2003) characterized the dose-response for cell replication rates as a J-shaped curve, indicating that cell division rates decreased below that determined for the unexposed case at low-exposure concentrations. In addition, these authors also used a hockey stick-shaped curve such that the dose-response for cell division rates remained unchanged from the baseline, rising only at 6 ppm (7.4 mg/m^3^) and higher exposure concentrations. This resulted in more conservative estimates of risk when used in the clonal expansion model for cancer.

In addition to the data from the two tumor bioassays, Conolly et al. (2003) included historical control data on 7,684 animals obtained from the National Toxicology Program (NTP) F344 rat inhalation and oral bioassays. The resulting model predicts the probability of a nasal SCC in the F344 rat as a function of age and exposure to formaldehyde. EPA reimplemented the Conolly et al. (2003) model, and first examined whether the code reproduced their results under identical conditions, inputs, and assumptions, including the use of all NTP historical controls. The corresponding fits to the tumor incidence data are compared in Figure 5-5 against Kaplan-Meier adjusted probabilities. There were small residual differences between the two implementations as reflected by the better fit to the control (0 ppm), 10 ppm and 15 ppm data in the EPA reimplementation, whereas a better fit to the 6 ppm data in the original Conolly et al. (2003) implementation (see Subramaniam et al. (2007) for a discussion of these differences).

Figure 5-5 Fit to the rat tumor incidence data using the model and assumptions in Conolly et al. (2003)

Fitted curves obtained by Conolly et al. (2003) is compared with EPA reproduction of these results under identical conditions, inputs, and assumptions, including the use of all NTP historical controls; there were minor residual differences among the implementations (see (Subramaniam et al., 2007)). The tumor incidence data are shown here by the Kaplan-Meier adjusted probabilities.

The BBDR modeling approach affords a convenient way to integrate multiple types of mechanistic information in modeling the time-to-tumor data, and visually it appears to fit these data well (as shown in Figure 5-5). Further clarification pertaining to the structure and calibration of the models in (Conolly et al., 2003, 2004) that are key to understanding model assumptions is provided in Appendix C.1.12 and Appendix D.2.2.

##### Benchmark modeling of cancer incidence and human equivalents within the range of the data

Benchmark concentrations (BMCs) and the corresponding 95% lower confidence bounds (BMCLs) were calculated at a benchmark response level (BMR) at the lowest end of the range of the observed data (U.S. EPA, 2012). BMCs and BMCLs at the BMRs of 0.005 and 0.01 extra risk were determined with the BBDR models. These were compared with values determined at the BMRs of 0.05 or 0.1 extra risk level to facilitate comparison with other chemicals. A BMR of 0.005 is lower than the lowest observed tumor response (0.0085), when corrected for survival, from the combined data from the Kerns et al. (1983) and Monticello et al. (1996) bioassays. Using this lower value is considered appropriate because the BBDR modeling incorporates information on regenerative cell proliferation, derived from cell labeling data, which may be considered a precursor response. The BBDR models (model 1 & model 2 below) used for this purpose provided good fits to the time-to-tumor incidence data, similar to the fit shown in Figure 5-5, and are based on the Conolly et al. (2003) model with the following modifications.

Model 1 is based on the more conservative model in Conolly et al. (2003), where the parameters governing the kinetics of normal and initiated cells were derived as hockey stick-shaped functions of flux, with a critical modification. Conolly et al. (2003) added historical control animals from all NTP studies to the data from the concurrent controls, whereas model 1 includes NTP historical data from only the inhalation route of exposure. This is because the incidence rate of nasal SCC is very different between these two categories of NTP historical studies, and the generally accepted practice is to not include studies from other routes of exposure when using historical controls (see (Subramaniam et al., 2007; Subramaniam et al., 2008) for an explanation of this issue). Model 1 is the same as Model E in Table III of Subramaniam et al. (2007).

Model 2 makes major modifications to Conolly et al. (2003) in regards model structure as well as values for input parameters. First, the shape of the dose-response for the division rates of normal (N) cells as a function of formaldehyde flux, α_N_(flux) [an input to the TSCE model], was monotone increasing without a threshold in dose, and obtained by fitting the 13-week cell replication data in Monticello et al. (1996). (See Appendix D.2.2 for a discussion pertaining to using the 13-week data.) The raw replicate animal data from this study was provided to EPA by the Hamner Institutes for Health Research. Second, the dose-response for the division rates of initiated (I) cells, α_I_(flux), was assumed to be a sigmoidal-shaped curve, increasing monotonically with flux from a background value up to an asymptotic value, and constrained by α_I_(flux = 0) ≥ α_N_(flux = 0). The death rate of initiated cells was given by the assumption, β_I_(flux) = κ∙α_I_(flux), where κ is an estimated constant. This model is discussed in detail as “model 15” in Appendix D.2.2. Furthermore, as in model 1, only the historical controls from inhalation studies were added to the concurrent controls.

Weekly averaged DPX concentrations as calculated by the PBPK model described in Appendix A of Subramaniam et al. (2007), a variant of the PBPK model in Conolly et al. (2000), were used. The model fits to the observed tumor incidence data, parameter values, and respective comparisons with Conolly et al. (2003) are provided in Appendix D.2.2. The results based on these models are included in Table 5-37. The BBDR modeling fit the time-to-tumor data much better than the Multistage Weibull model (see Appendix D.2.2).

The BMCs mentioned above and their corresponding BMCLs were then converted to their equivalent concentrations in humans (HECs). This extrapolation involved multiplication by two factors: (1) a duration adjustment of (6/24) × (5/7) to the laboratory exposure regimen in order to adjust for continuous exposure; (2) a ratio of regional gas dose in the F344 rat to that of humans for the upper respiratory tract region. The regional gas dose was based on formaldehyde flux to the nasal tissue obtained using CFD modeling in the rat and human (Kimbell et al., 2001b), Subramaniam et al. (1998). In addition, two other dose metrics were also used. As mentioned earlier, Schlosser et al. (2003) presented an alternate extrapolation based on DPX as the dose metric.

For the Multistage-Weibull time-to-tumor modeling, the first result presented is based on using inhaled formaldehyde exposure concentration for the second factor. Here, the default gas dose ratio for the extrathoracic region given by equation 4-18 of U.S. EPA (1994) is used. This is equal to the ratio of the quantity (V_E_/SA_ET_) calculated for the rat and human, where V_E_ is the minute volume and SA_ET_ is the surface area of the extrathoracic region (in this case, the nasal passages).

The average mass flux of formaldehyde (pmol/mm^2^-hour) to the entire surface of the airway lining, excluding surface lined by nonmucus-coated squamous tissue which is thought not to absorb formaldehyde, was used for the human extrapolation in all four of the models presented in the Table 5-37 (see discussion earlier in this Section, Computational fluid dynamic modeling). The HEC corresponding to a particular benchmark level in the rat was then calculated by assuming that continuous lifetime exposure to a given steady-state flux of formaldehyde, expressed in pmol/mm^2^-hour, leads to equivalent risk of nasal cancer across species. This approach is in line with that taken in equations 4-17 and 4-18 of U.S. EPA (1994). In the CFD modeling, flux in any region is proportional to the inhaled exposure concentration; i.e., flux = f × C_air_ where f is a constant of proportionality and C_air_ is the exposure concentration. Then, the human extrapolation is achieved by multiplying the duration adjusted benchmark level in the rat by the ratio of the proportionality constants for the rat and human (f_rat_/f_human_). This ratio was equal to 0.71 for the calculation by Schlosser et al. (2003) and equal to 0.46 in all the other calculations in Table 5-37. This discrepancy is largely due to different values in these calculations for the minute volume for the human; 7.5 L/min by Schlosser et al. (2003) corresponding to resting breathing, but 13.8 L/min for the other three calculations as per the default value prescribed in U.S. EPA (1994) corresponding to equal durations through the day of resting, sitting and light activity levels. EPA’s calculations in Table 5-37 are discussed further in the Appendix D.2.2. The minute volume used for the rat was 0.288 L/min.

The benchmark levels in the rat and the HECs obtained using the above methods and dose metrics are shown in Table 5-37. For a given benchmark response level, PODs and their corresponding HECs are remarkably similar across multiple models and internal dose metrics (formaldehyde inhaled flux to tissue and DNA-protein crosslink [DPX] concentrations).

Table 5-37 Benchmark concentrations and human equivalents using formaldehyde flux and DPX as dose metrics

Models | Rat benchmark conc (ppm) | | | | | Human equivalent conc^a^ (ppm)
Models | | BMR=0.005^b^ | BMR=0.01 | BMR=0.05 | BMR=0.1 | Dose metric^c^ | | BMR=0.005^b^ | BMR=0.01 | BMR=0.05 | BMR=0.1
Weibull^d^ with threshold (Schlosser et al., 2003) | BMC; BMCL | | 5.91; 5.58 | 6.12; 5.94 | 6.40; 6.22 | Flux | BMC; BMCL | | 0.75; 0.71 | 0.78; 0.76 | 0.82; 0.79
Weibull^d^ with threshold (Schlosser et al., 2003) | BMC; BMCL | | 5.91; 5.58 | 6.12; 5.94 | 6.40; 6.22 | DPX | BMC; BMCL | | 0.76; 0.71 | 0.79; 0.76 | 0.84; 0.81
Multistage Weibull time-to-tumor^e,^ ^g^ | BMC; BMCL | | 4.28; 3.96 | 5.93; 5.49 | 6.84; 6.34 | Exposure Conc | BMC; BMCL | | 0.21; 0.20 | 0.29; 0.27 | 0.34; 0.32
Multistage Weibull time-to-tumor^e,^ ^g^ | BMC; BMCL | | 4.28; 3.96 | 5.93; 5.49 | 6.84; 6.34 | Flux | BMC; BMCL | | 0.35; 0.33 | 0.49; 0.45 | 0.56; 0.52
Rat BBDR model 1^f^ | BMC; BMCL | 4.99^g^; 4.95 | 5.37^g^; 5.19 | | | Flux | BMC; BMCL | 0.42; 0.41 | 0.45; 0.43
Rat BBDR model 2^f^ | BMC; BMCL | 5.41; 5.25 | 5.75; 5.59 | | | Flux | BMC; BMCL | 0.45; 0.44 | 0.48; 0.46

Abbreviations: BMR= Benchmark response in terms of Extra Risk; BMC = benchmark concentration; BMCL = benchmark concentration; BBDR = biologically based dose-response; TWA = time=weighted average; DPX = DNA-protein crosslink; CFD = computational fluid dynamic; PBPK = physiologically based pharmacokinetic.

a Human benchmark levels were continuous environmental exposures that would result in steady-state flux (or DPX) levels in humans equal to the average flux (or weekly TWA DPX) levels in rats at the rat BMCs adjusted for 6 hours/day and 5 days/week. Values derived using flux as dose metric decrease by a factor of 1.4 if flux estimates based on Schroeter et al. (2014) are used instead of Kimbell et al. (2001a).

b The BMR of 0.005 was used only with the BBDR modeling because these models incorporate precursor response data related to cellular proliferation (see discussion in surrounding text).

c Flux and DPX levels were computed by CFD (Kimbell et al. (2001a), Subramaniam et al. (1998)) and PBPK modeling (Conolly et al. (2000)), respectively.

d p-value for Weibull model fit = 0.90, best fit obtained with a positive intercept on dose axis.

e P(d,t) = 1 − exp[-(q_0_ + q_1_d + q_2_d^2^ + … + q_k_d^k^)x t^z^]. q_0_, q_1_, q_2_, q_3_, q_4_ = 0, q_5_ = 2.9 × 10^–22^, z = 8.1. Curve passes through origin. Fit was judged by comparing fitted curve to Kaplan-Meir survival estimates since goodness-of-fit p-value was not provided by software package.

f Fit to time-to-tumor data with the BBDR approach was superior to that obtained from the multistage Weibull model. Because benchmark concentrations at 0.005 and 0.010 extra risk levels were reported when BBDR modeling was used, they were not calculated at the 0.05 and 0.1 levels.

g Roughly similar result was obtained with model in Conolly et al. (2003). BMC_005_ = 4.84 ppm and BMC_01_ = 5.48 ppm for their hockey-stick model as discerned from Figure 5 of their paper. BMCL values could not be estimated for that model since confidence bounds were not reported.

As discussed in Section 3.1, Schroeter et al. (2014) revised the dosimetry model of (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001), used for the flux estimates in the table above, to include endogenous formaldehyde production and to explicitly model formaldehyde pharmacokinetics in the respiratory mucosa. EPA estimated the extent to which the results in the above table change if flux estimates from Schroeter et al. (2014) are used. The average flux over nonsquamous regions of the rat nose is roughly one-third^66^ of that in the human, based on the dosimetry in Schroeter et al. (2014) in which endogenous formaldehyde is taken into account compared to a ratio of roughly one-half based on the dosimetry in Kimbell et al. (2001a). Thus, wherever flux is used as the dose metric, the benchmark concentrations calculated in the above table are not altered appreciably if the revised dosimetry model by Schroeter et al. (2014) is applied, decreasing only by roughly a factor of 1.4.^67^

##### Benchmark modeling of precursor lesion data in the rat: cell proliferation and hyperplasia

Benchmark concentrations based on signatures of increased cell proliferation are useful in that increased regenerative cell proliferation is assumed to be a contributory MOA—a factor that can lead to a greater likelihood that DNA damage becomes heritable mutations before it is repaired. Significantly increased cell proliferation as well as hyperplasia (increased cellular proliferation that is identified to be pathologically “abnormal” in tissues) has been observed in response to exposure to formaldehyde, as described in Section 3.2.4 (additional information in Appendix C.7.1).

###### Cell proliferation

Schlosser et al. (2003) used cell proliferation to represent an adverse response and modeled the dose-response for unit length labeling index measurements in F344 rats. They reported benchmark concentrations and 95% lower confidence bounds corresponding to 1%, 5%, and 10% increase in this index over the mean level for controls using dose-response functions that allowed for a threshold in dose.^68^ The corresponding HECs spanned a tight range of 0.44–0.47 ppm (0.54–0.58 mg/m^3^) (see Table 8 of their paper.)

The data used in their modeling were constructed using a cellular labeling index over several locations on the F344 rat nose, as reported by Monticello et al. (1996). The data from Monticello et al. (1996) represent the longest duration cell proliferation study available, which included measurements across a range of study time points and nasal regions. Due to methodological constraints intrinsic to all the available cellular labeling studies, including Monticello et al. (1996), these data are based on DNA labeling of actively proliferating cells only during the last day of exposure (see Appendix C.7 for additional discussion). Schlosser et al. (2003) averaged the data collected from several nasal sites after weighting by exposure time. This introduces some uncertainty because time-weighted averaging underweights early exposures (e.g., 12–13 weeks of exposure) that may have contributed significantly to carcinogenesis (see discussion later in this section under Uncertainty-variability in cell replication dose-response of normal cells); for instance, the few studies that investigated latent effects in rats (i.e., Wistar) did observe an increased tumor incidence at 1 to ≥2 years following high-level formaldehyde exposure lasting only ~13 weeks (Woutersen et al., 1989; Feron et al., 1988). Similarly, additional methodological uncertainties that are difficult to address experimentally include large site-to-site variation in the labeling (i.e., ≥10-fold); differences in the number of cells across nasal sites; and the possibility that histologic changes and thickening of epithelium that occur at later times for the higher doses likely affect the replication rate. These issues are discussed further and several other plausible dose-response curves for cell replication from Monticello et al. (1996) are developed (see Appendix D.2.2).

Other well-conducted studies of cellular proliferation using similar labeling methods help estimate the potential impact of these uncertainties in the benchmark concentrations calculated by Schlosser et al. (2003). In general, data from other studies investigating shorter-term formaldehyde exposure durations, as well as the data for shorter duration exposures in Monticello et al. (1996), routinely indicate proliferative effects at lower formaldehyde exposure levels within similar nasal regions^69^ (see Appendix C.7.1 for comparisons across various durations of exposure). As discussed in the Appendix, it appears reasonable to assume that all cell proliferation studies with formaldehyde exposures longer than 12 weeks are equally relevant to potential cancer development. The data available from medium and high confidence studies longer than 12 weeks, including multiple measures in Monticello et al. (1996), are arrayed in Figure 5-6, below, and point to a two- to-three-fold range of observed values below the benchmark concentration estimated by Schlosser et al. (2003), as represented by the dotted vertical lines in the figure. This comparison partly elucidates the uncertainty in the HEC values derived by Schlosser et al. (2003) to understand the cumulative effects of chronic formaldehyde exposure on cellular proliferation.

Figure 5-6 Cellular proliferation measured by DNA labeling in studies ≥12 weeks

Data from high and medium confidence studies (High/Med; H/M) exposing rats to formaldehyde for at least 12 weeks (wk), and up to 18 months (mos), were normalized to percentage change from controls to compare across the different metrics of proliferation reported (e.g., labeling index [LI]; unit length labeling index [ULLI]; incorporation of radiolabeled carbon). The regions compared typically included the lateral meatus (LM) in anterior regions (e.g., L1; L2; anterior LM), although one comparison was in related structures (i.e., nasoturbinates [NT] and maxilloturbinates [MT] in Wilmer et al. (1989). The DNA labeling procedures included bromodeoxyuridine (BrdU), thymidine (thym.), and radiolabel. Filled shapes represent statistical significance (p ≤ 0.05), as reported by the study authors. The vertical lines represent the rat BMDL_01_, as reported by Schlosser et al. (2003) and estimates which are two- and three-fold lower than the Schlosser et al. (2003) rat BMDL. References: Zwart et al. (1988); Wilmer et al. (1989); Monticello et al. (1996); Meng et al. (2010); Casanova et al. (1994); Andersen et al. (2010).

###### Hyperplasia

EPA modeled the incidence of basal hyperplasia reported by Woutersen et al. (1989) in a 28-month bioassay using Wistar rats. These animals were exposed to 0, 0.1, 1.0, and 9.8 ppm (0, 0.123, 1.23, and 12.05 mg/m^3^) formaldehyde and the observed incidences of hyperplasia were 0/26, 1/26, 2/28, and 14/26. The BMC and BMCL at the benchmark response of 0.1 extra risk were 1.68 and 1.108 ppm (2.07, and 1.36 mg/m^3^), respectively. The HEC corresponding to the BMCL is 0.1609 ppm (0.198 mg/m^3^) when adjusted for continuous human lifetime exposure, which is roughly three times lower than the HEC derived from the time-weighted averaged labeling index by Schlosser et al. (2003). It is useful to note that this value is roughly comparable to the LEC_0005_ derived from EPA’s modeling of the NPC risk from the NCI epidemiology data.

##### Extrapolation using a biologically based dose-response model

In the case of formaldehyde, there are multiple options available for extrapolating to human exposure scenarios which are typically at lower concentrations than the various HECs calculated above. Subsequent to their BBDR modeling (Conolly et al. (2003)) of nasal cancer in the rat, Conolly et al. (2004) developed a corresponding model for humans, which they used for the purpose of extrapolating the observed risk in the rat to human exposures. This human extrapolation model is conceptually similar to the modeling in Conolly et al. (2003) but does not incorporate any data on human responses to formaldehyde exposure. A particular contribution of this model toward extrapolation is that it uses, as input, DPX concentrations and values of local formaldehyde flux to the tissue as obtained from PBPK and fluid dynamic dosimetry models respectively (Subramaniam et al., 1998; Kimbell et al., 2001a; Conolly et al., 2000). The modeling in (Conolly et al., 2003, 2004), while still a statistical model where some key parameters are determined by model fit to the tumor data, incorporates more detailed biological hypothesis and mechanistic data than is normally employed in modeling cancer risk. Toxicodynamic models developed on the basis of an agent’s MOA, if robust, are generally preferred over default approaches for extrapolation, with the extent of extrapolation determined by model uncertainty (U.S. EPA, 2005a).

EPA’s evaluation of model robustness considered three criteria routinely implemented for biomathematical models (for example, PBPK models) where multiple parameters are estimated by fitting to observed data and the model(s) is/are then used in a predictive capacity for extrapolation (Barton et al., 2007).

- Model specification: Are there alternate model structures that describe the observed data and do they lead to different predictions? Are common model structures used across species?
- Model calibration: In the BBDR modeling the unknown parameters were estimated statistically using the maximum likelihood method to optimize the model fit to the available data. These data included tumor incidence data in animals as well as baseline incidence rates in humans. Does this calibration allow the model to reasonably approximate the observed data? In robustly calibrated models, the optimal fit is highly sensitive to small variations in the estimated parameters.
- Model prediction: The purpose of the BBDR modeling was to predict outcomes to human exposure scenarios (it was also used to better describe the available data). Accordingly, the criterion for robustness is whether the predictions are unique while also maintaining tight agreement with the calibration data; i.e., predictions should not be highly sensitive to parameters for which experimental data do not provide any information (note that this consideration runs counter to how sensitivity is used in evaluating model calibration). EPA employed a common practice in sensitivity analyses where one varies parameters by a small amount from estimated values and assesses impact on predictions.

In this section, we present extrapolations of the rat nasal cancer risk to humans carried out in Conolly et al. (2004). Continuous human lifetime extra risk estimates from this model following inhalation exposure to 1.0 ppb–1.0 ppm (1.23 µg/m^3^–1.23 mg/m^3^) formaldehyde concentrations are provided in Table 5-38, and compared with human risk estimates derived from EPA’s modeling of the NPC mortality in the NCI occupational epidemiology data (note: the comparison with mortality estimates appears appropriate since Conolly et al. (2004) had modeled the tumors as rapidly fatal). This comparison is provided only for perspective, noting in particular that NPCs are specific to tumors only in the human nasopharynx (see Section 3.2.5). Conolly et al. (2004) developed two clonal growth models based on using different representations of the low dose-response for the cell division rate as input data. The first, denoted as optimal in the table, was derived from using the best fit, a J-shaped curve, to the dose-response for the TWA of the cell labeling data in rats such that values at 0.7 ppm and 2.0 ppm (0.9 mg/m^3^ and 2.46 mg/m^3^) were below the control value; the second, presented as their conservative (in the sense of being more health protective) approach, was derived from using a hockey-stick shape to replace the J-shape in the low-dose portion of the optimal case such that values at the two lowest concentrations were the same as the control. In either case, risk estimates reported in Conolly et al. (2004) were based on using maximum likelihood estimate (MLE) values for all model parameters except the parameter kmu associated with formaldehyde’s mutagenic potential for which they used an upper-bound value; (kmu is the constant of proportionality that relates DPX concentrations to the probability of formaldehyde-induced mutation occurring per-cell generation).

The optimal model in Conolly et al. (2004) indicates lifetime human risk estimates to be substantially below baseline risk levels (i.e., negative values of extra risk) for formaldehyde exposures less than roughly 2 ppm (2.46 mg/m^3^), while their conservative model predicts values that do not appreciably exceed baseline levels (i.e., extra risk less than 10^−5^) for exposures less than 0.2 ppm (0.25 mg/m^3^). At the EC_0005_ benchmark concentration of 0.19 ppm (0.23 mg/m^3^) derived from the NCI occupational epidemiology data, the conservative model in Conolly et al. (2004) predicts roughly a 100-fold lower continuous lifetime risk than the central estimate indicated by EPA’s analysis of the epidemiology data. The difference is roughly the same at lower exposure concentrations, while at 1.0 ppm (1.23 mg/m^3^) the conservative model predicts a 1,000-fold lower value than EPA’s central estimate based on the epidemiology data (see Appendix D.2.2).

The maximum likelihood value of the parameter kmu was estimated to be zero in the modeling, leading to the inference by the authors that formaldehyde’s direct mutagenic action is not relevant to carcinogenicity in the rat or human, and that the observed tumor response in the rat can be explained on the basis of regenerative cellular proliferation in response to cell injury. These results have been interpreted by some to mean that exposures protective of the effects of cell proliferation are adequate to protect against formaldehyde-induced nasal cancers (Slikker et al., 2004; Conolly et al., 2004). The uncertainty in these estimates and conclusions are evaluated below.

Table 5-38 BBDR model (Conolly et al., 2004) estimated extra risk of SCC in human respiratory tract compared with EPA’s modeling of extra risk of NPC from the human occupational epidemiology data

Formaldehyde concentrations | 0.001 ppm | 0.01 ppm | 0.10 ppm^a^ | 1.0 ppm
Conolly et al. (2004) optimal estimate^b^ | −1.0 × 10^−5^ | −1.0 × 10^−4^ | −9.1 × 10^−4^ | −5.0 × 10^−3^
Conolly et al. (2004) conservative estimate^b^ | +3.1 × 10^−8^ | +3.2 × 10^−7^ | +3.5 × 10^−6^ | +2.7 × 10^−4^
EPA analysis-NCI NPC mortality MLE (UCL)^c^ | +1.2 × 10^−6^; (+2.1 × 10^−6^) | +1.3 × 10^−5^; (+2.3 × 10^−5^) | +1.8 × 10^−4^; (+4.1 × 10^−4^) | +2.7 × 10^−1^; (+8.7 × 10^−1^)

a For reference, the mortality-based LEC_0005_ derived from the NCI occupational data is 0.11 ppm (EC_0005_ is 0.19 ppm).

b Conolly et al. (2004) risk estimates were based on using MLE values for all model parameters except the parameter associated with formaldehyde’s mutagenic potential for which they used an upper bound.

c See Table 5-31; MLE = maximum likelihood estimate; UCL = 95% upper confidence limit.

##### Uncertainty in the dose-response estimates

The ratio of the BMCL to the BMC is a convenient way to express the statistical uncertainty in the benchmark concentration derived by a given model. Table 5-37 indicates this ratio to be tight (> 0.9) for the estimates derived from the rat nasal tumors. However, it is well-recognized (U.S. EPA, 2005a) that there is a large uncertainty inherent to using statistical models to extrapolate outside the range of observed data. The level of confidence in various components of the biologically based modeling approach and its use for extrapolation is next addressed; the relevant question is whether the BBDR modeling decreases uncertainty in extrapolating risk or, by explicitly identifying the sources of uncertainty, points to approaches and data needs that may help reduce the uncertainty.

###### Uncertainties and confidence in the BBDR modeling and extrapolation

EPA carefully evaluated the level of confidence and sources of uncertainties in different components of both the rat BBDR model and the corresponding human extrapolation model (Table 5-39). Seven issues that were evaluated are tabulated below and elaborated in more detail in Appendix D.2.2 and supporting references. Of these, issue numbers 3, 6 and 7—related to replication rates of normal and initiated cells and the use of historical control animals—were found to have major impacts on qualitative and quantitative conclusions drawn from the modeling and are briefly discussed below.

Table 5-39 Evaluation of BBDR modeling issues

| Issue | Supporting references for evaluation
1 | Confidence in FA airflow and flux model, and assessment of interindividual variability in FA flux; airway reconfiguration due to long-term dosing | Subramaniam et al. (1998); Kimbell et al. (1997a); Kimbell et al. (2001a); Subramaniam et al. (2008); Garcia et al. (2009); Morgan (1997); Monticello et al. (1996); Cohen Hubal et al. (1997); Kimbell et al. (1997b)
2 | Uncertainties in FA-DPX PBPK model | Subramaniam et al. (2007); Subramaniam et al. (2008)
3 | Uncertainties and variability in the rat cell labeling data, the derivation of cell division rates from these data, and their applicability to human cell division rates | Subramaniam et al. (2008); Conolly et al. (2004)
4 | Use of an approximate method by Hoogenveen et al. to solve the two-stage clonal expansion model equations | Subramaniam et al. (2007); Crump et al. (2005)
5 | Assumption that all observed SCC in rats were rapidly fatal; Model assumption of a time delay from occurrence of malignant cell to death | Subramaniam et al. (2007); Crump et al. (2005); Crump et al. (2008)
6 | Sensitivity of model results to the use of historical control animals drawn from all NTP cancer bioassays | Subramaniam et al. (2007); Crump et al. (2008)
7 | Uncertainties in assumed division and death rates of initiated cells | Subramaniam et al. (2008); Crump et al. (2008); Crump et al. (2009)

###### Uncertainty-variability in cell replication dose-response of normal cells

Use of the raw cell labeling data from (Monticello et al., 1991; Monticello et al., 1996) to calculate replication rates of normal cells for input to the TSCE models in (Conolly et al., 2003, 2004) involved several steps and assumptions. First, as previously shown, the first phase for early exposure periods Monticello et al. (1991) employed injection labeling with a 2-hour pulse labeling, whereas the second phase for longer exposure periods Monticello et al. (1996) used osmotic mini-pumps for labeling with a 120-hour labeling time. These data were pooled by using a normalization procedure for the injection labeled data. Second, the average values from the labeling (averaged over the replicate animals and after the above normalization) were weighted by the exposure times in (Monticello et al., 1991; Monticello et al., 1996) and averaged over the nasal sites. Thus, the data were combined into one TWA for each exposure concentration. Third, (Monticello et al., 1991; Monticello et al., 1996) used unit length labeling index (ULLI) to quantify cell replication within the respiratory epithelium. ULLI is a ratio between a count of labeled cells and the corresponding length (in millimeters) of basal membrane examined. Therefore, ULLI had to be converted to the per-cell labeling index (LI), which is the ratio of labeled cells to all epithelial cells, in this case, along some length of basal membrane and its associated layer of epithelial cells. This was accomplished by using data from a different experiment (Monticello et al., 1990a) where both quantities had been measured for two sites in the nose. Fourth, cell division rates were then calculated from the TWA using an approximation developed by Moolgavkar and Luebeck (1992).

Fifth, the empirical data could be used in Conolly et al. (2003) to directly calculate cell replication rates only for approximately the lower one-fourth of the full flux range (0−39,600 pmol/mm^2^-hour) needed to model the bioassay data. The unknown cell replication rates for the upper three-fourths of the flux range were determined by linear interpolation to a maximum cell replication rate that was estimated as a statistical parameter fit to model predictions of the tumor incidence data (see (Subramaniam et al., 2008) for further details and biological implications of this procedure).

Finally, because there are no equivalent labeling index data available for the human respiratory epithelium, the above dose-response for normal cell replication derived for the rat was also directly assumed to apply to the human except for different values for the fraction of rat and human nasal epithelial cells capable of dividing (Conolly et al., 2004).

The TSCE model is generally sensitive to normal cell division rates, and there are considerable uncertainties (quantitative and qualitative) and variability in the dose-response for the replication rates of normal cells (α_N_) as characterized in the above steps. For example, Figure 5-7, below, shows α_N_ as a function of formaldehyde flux to the rat nasal epithelial tissue [using only values derived from the continuous ULLI data in (Monticello et al., 1996)]. Corresponding to any particular dose (in terms of formaldehyde flux to tissue) α_N_ varies by one to two orders of magnitude. As shown in Appendix D.2.2, a variety of cell replication dose-response curves can be drawn to fit these data, and the use of an exposure TWA of cell labeling data over sites was found to be problematic on multiple accounts. Furthermore, the formula relating LI to α_N_ was for continuous labeled data and its use for pulse labeled data, as evaluated in the appendix, was found to be extremely uncertain.

The results in Table 5-38 for the optimal and conservative models in Conolly et al. (2003) represent a sensitivity analysis of the impact on risk estimates of varying the dose-response for [underlined: normal] cell replication rates at the low-dose range, and the differences between the two model results point to large variations in predicted human risk estimates from incorporating some of the variability and uncertainty in normal cell division rates in inputs to the TSCE model. In the neighborhood of the POD from the observed occupational epidemiology data, these models compute extra risk estimates of −9.1 × 10^−4^ and +3.5 × 10^−6^ respectively compared to a value of +4.1 × 10^−4^ indicated by the epidemiology data.

Figure 5-7 Dose-response for normal cell division rate, α_N_, versus formaldehyde flux to tissue for the F344 rat nasal epithelium

Values were derived from continuous unit length labeled data by Monticello et al. (1996). Each point represents a measurement for one rat, at one nasal site, and at a given exposure time. Data shown for six nasal sites (legend, nasal sites are as denoted in original paper) and four exposure durations (13, 26, 52, 78 weeks). For comparison purposes, the double black bars on the y-axis indicate the extent of difference between two curves, mod0 and mod5, for the dose-response for cell division rates of initiated cells.

The assumption in Conolly et al. (2004) that cell division rates exhibit a similar dose-response across rats and humans appears uncertain (Conolly et al. (2004) did consider different values for rats and humans for the fractions of cells with replicative potential) (see Appendix D.2.2). EPA was unable to find a rationale for this assumption in the literature. To the contrary, it seems possible that basal cell division rates may scale allometrically across species, considering that enzymatic metabolism is likely to play a role in mitosis. [For example, West and Brown (2005) argue that DNA nucleotide substitution rates and inverse of lifespan scale as mass to the inverse one-fourth power.]

Miller et al. (2017) found the modeling in Conolly et al. (2004) [that is, their human extrapolation model] to be sensitive to the fraction of cells considered to have replicative potential in the human respiratory tract, a parameter in the human model. For example, added risk over background increased (by 87%) from −1.0 × 10^−3^ to −1.3 × 10^−4^ at 0.4 ppm exposure concentration but decreased (by 127%) from +7.7 × 10^−4^ to −2.1 × 0^−4^ at 2.0 ppm, when this parameter was changed from that experimentally observed by Mercer et al. (1994) for various cell types to a value of 1.0 (i.e., all cells to have replicative potential) for the nonsmoking population at resting breathing.

Miller et al. (2017) also reported new results obtained with the Conolly et al. (2004) model in regards the site distribution of extrapolated human risk estimates over the respiratory tract. At 0.2 ppm and 1.2 ppm (0.25 mg/m^3^ and 1.48 mg/m^3^) inhaled exposure concentrations of formaldehyde, the highest risk was predicted to occur in nasal tissue that received the lowest formaldehyde flux, but which comprised the largest surface areas. Based on the flux patterns displayed in Kimbell et al. (2001), this likely overlaps with the human nasopharyngeal region, and suggests an important role for dosimetry in regards the epidemiological observation of nasopharyngeal carcinomas. For the high exposure concentrations (3.6 ppm and 4.5 ppm; 4.43 mg/m^3^ and 0.62 mg/m^3^), the highest risk region was instead predicted to occur in regions of the nose that received intermediate levels of formaldehyde flux.

###### Kinetics of initiated cells

There are no data on initiated (I) cells (the available empirical cell labeling data are for normal [N] cells). Therefore, Conolly et al. (2004) assumed relationships that linked the division rate, α_I_, and death rate, β_I_, for initiated cells to the division rate for normal cells, α_N_, as a function of local formaldehyde flux (since local flux was the most sensitive dose metric):

α_I_ ( f l u x ) = α_N_ ( f l u x ) × { c_1_ − c_2_ ⋅ max [ α_N_ ( f l u x ) − α_N b a s a l_ , 0 ] } - (Eq. 5-4)

β_I_ ( flux ) = α_N_ ( flux ) , for all values of flux . − (Eq. 5-5)

where c_1_ and c_2_ are constants estimated by fitting the clonal expansion model to the tumor incidence data. No biological rationale was provided for these assumptions; however, these assumptions allowed for a good fit to the rat tumor incidence data. The TSCE model is known to be very sensitive to the kinetics of initiated cells, and the authors did not examine whether other expressions would also fit the rat data but lead to different predictions of human risk. Therefore, to evaluate the sensitivity of model predictions to the assumed relation (Eq. 5-4) between α_I_ and α_N_ in the low flux region, EPA slightly modified this relation for α_I_(flux) for flux <475 pmol/mm^2^-hour, while keeping it identical to the values in Conolly et al. (2004) for 475 <flux levels <39,300 pmol/mm^2^-hour, and retaining the biological constraints imposed on it in the original model (i.e. mod0 in Table 5-40). The sensitivity analysis evaluated the effect both upon the fit to the rat tumor incidence data and the predictions of human risk. The changes made for the sensitivity analysis were small enough so as not to affect the model calibration.

Six such modified implementations of α_I_(flux) were considered (see mod-1, mod1, … mod5 in Figure 5-8 and in Table 5-40), in each case constrained to be small enough that they did not degrade the fit to the rat tumor incidence data when applied in the rat model or the fit to background incidence rates in the U.S. population when applied in the human model. The maximum extent of these modifications to the assumed replication rates of initiated cells is overlaid by the double black bars in Figure 5-7, above, on the rates for normal cells, α_N_(flux), that are derived from empirical data. As seen in the Figure, the extent of the modifications is extremely small in relation to the empirical variability seen in normal cells. Thus, the modifications considered in the sensitivity analysis appear biologically reasonable.

EPA’s sensitivity analyses retained the same values for β_I_ (equation 5-5) as considered in the original analysis. However, the ratio α_I_:β_I_ over the flux range in the modeling was closely monitored. Because this ratio represents the growth advantage of initiated cells in the model, it was kept close to the value of 1.0, similar to the range of 0.96−1.07 for the values of α_I_/β_I_ in (Conolly et al., 2004) [mod0]. In the sensitivity analysis, α_I_/β_I_ varied from 0.96−1.07 in mod-1; 0.96−1.08 for mod1, mod2, mod3, mod4; and 0.96−1.10 for mod5. Table 5-40 provides MLEs of continuous lifetime human extra risk estimates at 0.15 ppm (0.18 mg/m^3^) exposure concentration for the original Conolly model (mod0) and compares those derived from the above modifications. For perspective, the table also compares with human risk estimates derived from EPA’s modeling of the NPC mortality^70^ in the NCI occupational epidemiology data (see Section 5.2.1, Derivation of NPC unit risk estimates based on human data).

Figure 5-8 Small variations to α_I_(flux) for flux <475 pmol/mm^2^-hr carried out for sensitivity analysis

Mod0 is the original model in Conolly et al. (2004); mod-1 decreases α_I_ and mod1-5 increase α_I_ in mod0 for low flux.

Table 5-40 Sensitivity of BBDR modeled human SCC risk at 0.15 ppm to small variations in normal (α_N_) and initiated (α_I_) cell replication rates

Model^*^ | Extra risk
mod0: Conolly et al. (2004), J-shaped α_N_, α_I_ | –1.0 × 10^−3^
mod-1: Decrease α_I_ for low flux in mod0 | –1.5 × 10^−3^
mod1: Increase α_I_ for low flux in mod0 | –3.0 × 10^−4^
mod2: Increase α_I_ for low flux in mod0 | +9.0 × 10^−5^
mod3: Increase α_I_ for low flux in mod0 | +3.0 × 10^−4^
mod4 Increase α_I_ for low flux in mod0 | +9.0 × 10^−4^
mod5: Increase α_I_ for low flux in mod0 | +3.0 × 10^−3^
Conolly et al. (2004), hockey-stick shaped α_N_, α_I_ | +5.7 × 10^−6^
EPA analysis of NCI NPC | +5.5 × 10^−3^

* See Figure 5-8 for depiction of mod0, mod-1, mod0-5.

The results in this table indicate that extremely small differences in assumptions for α_I_ appear to have extremely large effects on the human model predictions. This analysis is continued in Appendix D.2.2, where similar sensitivity of model predictions is demonstrated over a large range of exposure concentrations. Larger variations in α_I_ (see (Crump et al., 2008)), while still in agreement with the model constraint of reproducing the observed tumor incidence data and the background rate of lung tumors in humans, considerably broaden the range of predicted risk on either side (below and above) of the baseline risk. Such an extreme sensitivity indicates that the formaldehyde human TSCE model is unstable in response to the slight perturbations carried out to the assumed values of α_I_ and is therefore not robust. It is well known that models are generally uncertain outside of the range of the data over which they were calibrated (Crump et al., 2010) and this is indeed the case with the rat BBDR model. As discussed by (Crump et al., 2008; Crump et al., 2009), the human extrapolation BBDR model, on the other hand, is noteworthy for its extreme uncertainty at [underlined: all] exposure concentrations, above as well as below the HECs that were calculated in the benchmark modeling section.

There are currently no data of any kind, even in rats, to inform the effect of formaldehyde on the kinetics of initiated cells. However, assuming that initiated cells related to tumors in the respiratory tract can be identified and their division rates measured, it is reasonable to suppose that these rates would be at least as variable as division rates of normal cells. Based on the normal variation in such rates observed in normal cells in Figure 5-8, and the extreme sensitivity of the formaldehyde model to small differences in assumed division rates of initiated cells, EPA concluded that it would be impossible to measure these accurately enough to lead to any substantive reduction in the large uncertainty in risk estimated by this model.

###### Use of historical control animals

Because SCC in the nose is a rare tumor, (Conolly et al., 2003, 2004) included in their model 7,684 control rats from all NTP cancer bioassays in addition to the 347 control animals in the Kerns et al. (1983) and Monticello et al. (1996) inhalation bioassays used in the dose-response modeling. In general, the inclusion of all NTP historical control animals regardless of exposure route, time of study, etc. is problematic because there are legitimate questions regarding comparability of results in rats from different stocks, studied at different times, in different laboratories, and by different routes of exposure and evaluated by using somewhat different pathological procedures (Rao et al., 1987; Haseman and Hailey, 1997). In particular, the incidence rate in the inhalation historical controls was found to be an order of magnitude lower than the rate in all historical controls combined (see (Subramaniam et al., 2007)). Therefore, EPA examined the sensitivity of the BBDR model predictions to the use of historical NTP control animals by restricting the historical controls to only inhalation studies or by using only the concurrent controls.

When the NTP control data were restricted to those animals from NTP inhalation studies, the upper-bound human risk estimate obtained by Conolly et al. (2004) (i.e., with everything else in their modeling retained unchanged) was increased by 50-fold (Crump et al., 2008). If only concurrent controls are used, as is normally the practice in dose-response analysis of animal bioassays, the Conolly et al. (2004) model for extrapolation of risk to humans becomes numerically unstable, i.e., the MLE and upper-bound estimates of risk become infinite (Subramaniam et al. (2007), Crump et al. (2008)).

###### Overall confidence in the formaldehyde BBDR models

The other issues listed in Table 5-39 are evaluated at length in Appendix D.2.2. Although CFD model predictions of formaldehyde flux to the respiratory lining have not been verified experimentally (due to formidable experimental challenges), predictions from other models that use the calculated formaldehyde flux as input have been shown to agree with various kinds of available data, and thus project a reasonable, albeit indirect, level of confidence in the formaldehyde dosimetry modeling in both the rat and human nasal passages (see Appendix D.2.2). The CFD models of formaldehyde flux are based on data collected from a single individual of each species. Therefore, interindividual differences in regional dosimetry, particularly in the human, are not accounted for (Subramaniam et al., 2008; Garcia et al., 2009).

Repair of DPX was assumed to be rapid and complete in 18 hours in the PBPK model for DPX (Conolly et al., 2000); this assumption was found to be highly uncertain (Subramaniam et al., 2008). While it has no impact on the rat BBDR model predictions (see Appendix D.2.2), the impact of this assumption on the human extrapolation model, on the other hand, was significant (Crump et al., 2008). Furthermore, more recent results by Lai et al. (2016) indicate that in vivo DPX repair may be slow and that DPX readily accumulates long-term in the nasal respiratory tissue in contrast to its rapid hydrolysis in vitro.

In summary, the human extrapolation modeling in Conolly et al. (2004) is extremely uncertain on two accounts, and does not provide robust measures of human nasal SCC risk at [underlined: any] exposure concentration. Therefore, the human extrapolation model is not used in this assessment to directly calculate risk at human exposure scenarios. On the other hand, the rat BBDR modeling improves the dose-response modeling of the observed nasal cancers in the F344 rat, and multiple BBDR model implementations provide similar estimates of risk and confidence bounds in the general range of the observed rat tumor incidence data. Therefore, the rat BBDR models are used to calculate benchmark concentrations for PODs, and the benchmark response was extended slightly below the observed. There is reasonable confidence in flux estimates derived from the rat and human CFD models, which were accordingly used in deriving HECs corresponding to these PODs. A candidate RfC and candidate unit risk estimates using these values are included in the following section.

##### RfC approach for precursor lesion data in the rat: cell proliferation and hyperplasia

The highly curvilinear and steeply increasing dose-responses for DPX formation and cell proliferation, concomitant with the highly nonlinear observed tumor incidence in the F344 rat, have led to mechanistic arguments that formaldehyde’s nasal carcinogenicity arises only in response to significant cytotoxicity-induced regenerative cell proliferation (Swenberg et al., 2011; Morgan, 1997; Conolly et al., 2002). In particular, Conolly et al. (2003) and Slikker et al. (2004) inferred from BBDR modeling results that the direct mutagenicity of formaldehyde is less relevant compared to the importance of cytotoxicity-induced cell proliferation in explaining the rat tumor response. Thus, candidate RfCs (cRfCs) derived from available experimental data relevant to this mechanism are presented and discussed. These cRfCs are interpreted as formaldehyde concentrations below which it is unlikely that hyperplastic lesions develop or that cancers arising from cytotoxicity-induced regenerative cell proliferation occur. In this interpretation, cytotoxicity-induced regenerative cell proliferation, which increases the probability of errors in DNA replication, and the subsequent development of hyperplastic lesions, are considered to be precursor events that, if protected against, would prevent these mechanisms from contributing to the cancer response. Below these cRfCs, formaldehyde may still increase the risk of nasal or upper respiratory cancer through direct mutagenicity or other mechanisms, but the magnitude of cancer risk may be significantly lower due to the absence of increased cellular proliferation or hyperplasia.

The following benchmark PODs and corresponding HECs were developed based on increased cell proliferation as well as hyperplasia: (a) 0.44 ppm (0.54 mg/m^3^) corresponding to the BMCL_01_ in Schlosser et al. (2003), and roughly two- to three-fold lower estimates based on examining data from other cell labeling studies (as discussed above in the section on modeling precursor lesion data), resulting in an overall range from 0.18 to 0.54 mg/m^3^; and (b) 0.16 ppm (0.20 mg/m^3^) based on EPA’s modeling of the incidence of basal hyperplasia reported by Woutersen et al. (1989) in Wistar rats. To these values, it is necessary to apply a UF = 3 to reflect other uncertainties in extrapolating from animals to humans and a UF = 10 to account for human variability (total UF = 30). This results in cRfCs that range from 0.006 mg/m^3^ to 0.018 mg/m^3^ when based on cell proliferation data and a cRfC of 0.007 mg/m^3^ from the hyperplasia data.

As noted earlier, it has been argued that the rat nasal tumors can be quantitatively explained based solely on formaldehyde’s cytotoxic potential. In accordance with this point of view, a cRfC estimated from benchmark concentrations derived using the two rat BBDR models may be a reasonable approximation for the dose at which there is no regenerative cell proliferative contribution to the nasal or upper respiratory cancer response. A cRfC of 0.017 mg/m^3^ may be obtained in this manner corresponding to the average HEC estimated using the two models at a benchmark response of 0.005 extra risk reduced by a UF of 30. This value is encompassed by the overall range of 0.006–0.018 mg/m^3^ obtained as explained above for the cRfCs based on cell proliferation and hyperplasia.

However, Chapter 1 of this assessment also provides multiple lines of evidence that the direct mutagenicity of formaldehyde plays a key role in its carcinogenicity. Cytogenetic effects in occupational studies and the formation of DPXs in experimental animals have been reported at exposures well below those considered to be cytotoxic (e.g., approximately 0.7–2 ppm or 0.9–2.5 mg/m^3^ in rats), and as noted earlier, DPX formation was detected in rats at exposures ranging from 0.3 ppm (0.37 mg/m^3^) to 15 ppm (18.5 mg/m^3^). The DPX dose-response shows a trend consistent with an increase over baseline levels at 0.7 ppm (0.86 mg/m^3^), which becomes statistically significant at 2 ppm (2.46 mg/m^3^) and above.

Furthermore, the previously mentioned inference that formaldehyde’s direct mutagenic action is relatively irrelevant to describing the observed rat tumor response was found to be extremely uncertain in EPA’s uncertainty analysis. A reanalysis presented in Subramaniam et al. (2007) indicated that, depending on the choice of control animals and alternate model assumptions, a large contribution from formaldehyde’s mutagenic potential may be needed to explain formaldehyde carcinogenicity at low dose as well as in describing the observed tumor incidence. Finally, as discussed in Section 3.2.5, Evidence on mode of action for URT cancers, genotoxicity is itself interpreted to be one of the mechanisms by which formaldehyde exerts its cytotoxic action. Thus, it is difficult to argue for a demarcation along the concentration axis of one MOA relative to the other. Therefore, because formaldehyde-induced tumors are not explained only by the cell proliferative MOA at any exposure, and since EPA does not develop an RfC specifically for one MOA when other MOAs also contribute to the tumor response, an RfC approach is not used.

##### Low-dose risk without extrapolating models below the observed data

The various arguments presented in the last two paragraphs of the previous section on an RfC-like approach for cancer, particularly regarding formaldehyde’s direct mutagenic potential, provide greater support for a low-dose linear approach in extrapolating low-dose formaldehyde cancer risk from the rat data. And, as previously discussed and based on a detailed analysis conducted according to EPA’s cancer MOA framework (U.S. EPA, 2005a), it was concluded that there is strong and consistent evidence to support that both MOAs (i.e., mutagenicity and cytotoxicity-induced regenerative proliferation) contribute to nasal cancers caused by formaldehyde inhalation exposure (see Section 3.2.5 for details). In accordance with the EPA cancer guidelines (U.S. EPA, 2005a, b), given the strong evidence for mutagenicity as a contributing MOA and the evidence-based understanding that mutagens can give rise to cancers with an apparently low-dose linear response, this extrapolation was carried out as a straight line drawn to the origin from the HEC corresponding to the BMDL. Unit risks so calculated are shown in Table 5-41 below. The unit risks corresponding to BMRs at the 0.005 or 0.01 extra risk levels, span a remarkably tight range, 0.01−0.03 per ppm, across the different methods when internal dose metrics, formaldehyde flux to the tissue or formaldehyde induced DPX, are used.

Table 5-41 Unit risks based on rat nasal tumors^a^

Models | Dose metric | Unit risk extrapolations from PODs at various BMCL’s (per ppm)
Models | Dose metric | BMCL_005_ | BMCL_01_ | BMCL_05_ | BMCL_10_
Weibull with threshold (Schlosser et al., 2003) | Flux | | 0.014 | 0.066 | 0.127
Weibull with threshold (Schlosser et al., 2003) | DPX | | 0.014 | 0.066 | 0.127
Multistage Weibull time-to-tumor | Exposure Conc | | 0.051 | 0.183 | 0.317
Multistage Weibull time-to-tumor | Flux | | 0.031 | 0.111 | 0.192
Rat BBDR model 1 | Flux | 0.012 | 0.023
Rat BBDR model 2 | Flux | 0.011 | 0.022

a Unit risks derived using flux as dose metric increase by a factor of 1.4 if flux estimates based on Schroeter et al. (2014) are used instead of Kimbell et al. (2001a). Also, see other footnotes from Table 5-37.

In conclusion, use of biologically based modeling allowed the use of various data, including mechanistic information, in an integrated manner for modeling the incidence of nasal SCC in F344 rats and for deriving benchmark levels for extrapolation. A conventional multistage Weibull time-to-tumor modeling was also used to model these data; however, the biologically based models provide better fits to the tumor incidence data. For a given benchmark response level, PODs and their corresponding HECs are remarkably similar across multiple models and internal dose metrics (formaldehyde inhaled flux to tissue, DPX concentrations) and are comparable (within a factor of 2–4) to values obtained using inhaled exposure concentration. Biologically based clonal expansion models were carefully evaluated for directly extrapolating the rat nasal cancer risk to human exposure scenarios. Predictions using these models for humans were found to be not robust at any exposure concentration. Accordingly, the clonal expansion modeling of the rat data was employed to derive multiple PODs and corresponding HECs but not used for directly extrapolating to human exposure scenarios.

#### Selection of a Unit risk Estimate for Nasal Cancers

The unit risk estimates derived using the available human and animal data on nasal cancers are similar (see Table 5-42), with the human estimate being only slightly lower than those values estimated using rat bioassay and mechanistic data.

Table 5-42 Comparison and basis of unit risk estimates derived from nasopharyngeal cancer in humans and nasal squamous cell carcinomas in rats^a^

| Based on human NPC | Based on nasal SCC in the rat
Study/endpoint | Beane Freeman et al. (2013) (NCI industrial cohort): NPC mortality | Monticello et al. (1996); Kerns et al. (1983): Incidence of nasal SCC in rats
Model features | Estimation of IUR using Poisson regression model and life-table analysis:; - U.S. national incidence data for NPC; - U.S. national all-cause mortality data to account for competing causes of death.; - Regression coefficients from loglinear models of nasopharyngeal cancer (NPC) mortality (exposed and unexposed workers); - Linear low-dose extrapolation from LEC | Modeling of tumor incidence used results from multiple mechanistic and statistical models, including BBDR modeling. Mechanistic information included:; - Dosimetric (CFD) modeling of formaldehyde flux to rat, monkey, and human airway lining^b^; - PBPK model for rats incorporating doseresponse data on DPXs^c^; - site-specific cell labeling measurements in nose^d^; A linear low-dose extrapolation from human equivalent dose at BMCL was employed
POD | 95% lower bound on concentration at 0.05% incidence (approx. 0.05 ppm) | 95% lower bound on concentration at 0.5% and 1.0% extra risk levels (0.33 to 0.46 ppm)
Unit risk estimate | 7.4 × 10^−3^ per mg/m^3^; (9.1 × 10^−3^ per ppm) | 8.9 × 10^−3^ to 1.8 × 10^−2^ per mg/m^3^; (1.1 × 10^−2^ to 2.2 × 10^−2^ per ppm)

a Note that these estimates are provided for comparison purposes and do not represent ADAF-adjusted values. ADAF = agedependent adjustment factor; only results based on internal dose metrics are shown in this Table for the estimates extrapolated from the rat nasal SCC data.

b Kimbell et al. (2001a).

c Subramaniam et al. (2007).

d Monticello et al. (1996).

A comparison of the unit risk estimates based on human and rodent data summarized above reveals that the different databases yield similar estimates, particularly when estimates based on internal dose metrics (flux and DPX) are used. When data from epidemiological studies of sufficient quality are available, these data are generally preferred for estimating risks (U.S. EPA, 2005a). In the case of formaldehyde, the NCI epidemiological study (Beane Freeman et al., 2013) is a high-quality study for the purposes of deriving quantitative risk estimates. Although there are uncertainties inherent in estimates from both the human and rodent databases, the estimates based on the human data are considered better estimates of the risk to humans.

Next, given that it was concluded in Section 3.2.5 that a mutagenic MOA was operative for URT cancers, the unit risk estimate for NPC is adjusted for potential increased early-life susceptibility, in accordance with EPA guidelines (U.S. EPA, 2005b) (see Section 5.2.4).

#### Uncertainties and Confidence in the Unit Risk Estimate for Nasal Cancers

The strengths and uncertainties in the unit risk estimate for NPC incidence are summarized in Table 5-43. One of the largest sources of uncertainty in the NPC estimate has to do with the rarity of the cancer and, thus, the small number of exposed cases (n = 8) that informed the dose-response analysis.

Table 5-43 Strengths and uncertainties in the cancer type-specific unit risk estimate for nasopharyngeal cancer

Strengths | Uncertainties
- Estimated from data that is directly relevant to humans.; - Based on the results of a large, high confidence epidemiology study involving multiple industries with detailed, individual cumulative exposure estimates and allowance for cancer latency.; - Low-dose linear extrapolation is supported by a mutagenic mode of action (i.e., not a default).; - Similar unit risk estimates derived using rat bioassay and mechanistic data on nasal cancers. | - NPC is a very rare cancer. This study followed more than 25,000 workers for over 40 years and observed a statistically significant increase in RR associated with the highest category of average exposure intensity, however, only 10 cases occurred. The small number of deaths creates uncertainties for the dose-response modeling (borderline significant trend test for cumulative exposure including exposed and unexposed personyears, p = 0.07).; - Uncertainty about optimal exposure metric(s). Cumulative exposure is the standard metric used for unit risk estimates. Use of cumulative exposure assumes equal importance of concentration and duration on cancer incidence; yet associations with peak exposure in epidemiological studies and the nonlinear shape of the dose-response from animal bioassays suggests greater influence of concentration.; - Although statistically significant increases in risk for NPC were reported by multiple studies for several metrics of exposure (duration, cumulative, time since first exposure, peak), the relationship with cumulative exposure in the study used for IUR derivation was less precise (p-trend = 0.07 based on the regression coefficient for the continuous model).; - Low-dose extrapolation below the POD is inherently uncertain. The presence of endogenous formaldehyde may have an effect on the delivered formaldehyde. Schroeter et al. (2014) and Campbell Jr et al. (2020) provide perspectives on this issue. Furthermore, the contribution of endogenous formaldehyde and its variability on background disease processes and dose-response remains uncertain.

Based on the attendant strengths and uncertainties outlined above, there is medium confidence in the unit risk estimate for NPC incidence.

### 5.2.2 Unit Risk Estimate for Myeloid Leukemia

A judgment that the evidence demonstrates that formaldehyde inhalation also causes myeloid leukemia was based on robust human evidence of increased risk in groups exposed to occupational formaldehyde levels. Supporting mechanistic evidence consistent with leukemia development is provided across numerous studies of peripheral blood isolated from exposed workers, including evidence of mutagenicity and other genotoxic damage in lymphocytes and myeloid progenitors, and perturbations to immune cell populations.

The animal evidence is indeterminate and, although notable uncertainties remain (see Section 3.3.3), the findings to date suggest either a lack of concordance across species or a lack of long-term studies in animal models that characterize the disease process in humans for leukemia. Leukemia was not increased in two well-conducted chronic bioassays of rats or mice, and the available animal data provide weak mechanistic support for LHP cancers. No MOA has been established to explain how formaldehyde inhalation can cause myeloid leukemia without systemic distribution (inhaled formaldehyde does not appear to be distributed to an appreciable extent beyond the URT to distal tissues). Differences in physiology between humans and rodents, as well as the apparent relative insensitivity of rodent models to reflect the human pathogenesis of AML (Eastmond, 1997), may together contribute to the potential lack of concordance between the abundant human epidemiological data and the more limited results (e.g., most bioassays did not examine tissues relevant to LHP cancers in detail) from rodent bioassay data. Accordingly, no animal studies were sufficient for use in deriving a unit risk estimate.

Results from the follow-up of mortality from LHP cancer in the same occupational cohort were used to derive a unit risk estimate for myeloid leukemia. In this study, however, there is no apparent association between myeloid leukemia mortality and cumulative exposure. A clearer association is observed with peak exposure, though it is not statistically significant in the latest follow-up (in an earlier 1994 follow-up of that study, myeloid leukemia mortality was statistically significantly associated with peak exposure; see Section 3.3.3). Although multiple approaches for deriving a unit risk estimate for myeloid leukemia were explored, EPA did not develop an approach based on the peak exposure metric because EPA deemed the uncertainty associated with the peak exposure metric and the difficulties in translating risk from peak exposure to risk from chronic low-level exposure to be prohibitive.

Instead, EPA explored alternative approaches for deriving a unit risk estimate for myeloid leukemia based on cumulative exposure (details in Appendix D.2.3). Specifically, although an association between myeloid leukemia and cumulative formaldehyde exposure was not apparent in the key exposure-response study, there are indications that this may, at least in part, reflect a misclassification of myeloid leukemia deaths on death certificates. (Percy et al., 1981; Percy et al., 1990) have reported that myeloid leukemia is often recorded as “leukemia” (not otherwise specified) on death certificates and hence underreported]. The best available approach (see Appendix D.2.3) was to estimate a unit risk for myeloid leukemia using the regression coefficient for myeloid and other/unspecified leukemias combined; this cancer grouping had a stronger association with cumulative exposure in the key exposure-response study than did myeloid leukemia alone and it captures the unclassified myeloid leukemias with the least inclusion of nonmyeloid leukemias. However, this estimate was concluded to be too uncertain and ultimately was not incorporated into the IUR.

#### Derivation of Myeloid Leukemia Unit Risk Estimates Based on Human Data

##### Choice of Epidemiology Studies

As noted previously, it was determined that the evidence demonstrates that formaldehyde inhalation exposure can cause myeloid leukemia (ML). While several studies of cancer in workers exposed to formaldehyde evaluated exposure-response relationships, most reported the results of categorical analyses, only a few reported risk estimates in relation to changes in formaldehyde concentration or cumulative exposure rather than duration of exposure, TSFE, probability of exposure, or exposure intensity score, measures which are not generally adequate for the derivation of cancer unit risk estimates.

One high confidence result from Beane Freeman et al. (2009) provided dose-response information on the follow-up of the large National Cancer Institute (NCI) retrospective cohort mortality study [originally described by Blair et al. (1986)] of workers at 10 U.S. plants producing or using formaldehyde. A second high confidence result from (Hauptmann et al., 2009) presented dose-response information from a large case-control study of embalmers and funeral directors [originally described by (Walrath and Fraumeni, 1983, 1984; Hayes et al., 1990) and not considered individually for IUR derivation]. Because of limitations in the exposure assessment, this study, while useful for hazard assessment, was not used by EPA to derive quantitative risk estimates. Of primary concern, the worker histories were obtained from surrogate responders (next of kin who had worked in the funeral home with the study subject and coworkers). There is substantial uncertainty in the application of this approach to variables such as number and duration of embalmings per calendar period and frequency of spills per calendar period, variables that are needed in the study’s exposure model to estimate cumulative exposure. Furthermore, considerable amounts of data were missing. Thus, although the results of the Hauptmann et al. (2009) study were supportive of the hazard assessment, the larger uncertainty in the quantitative estimates than other available studies resulted in no POD being derived. A third high confidence result from (Meyers et al., 2013) and one medium confidence study (Coggon et al., 2014) reported some information on dose-response but did not report quantitative metrics of cumulative exposure that could be used to derive an IUR for ML.

The available high and medium confidence epidemiology studies of myeloid leukemia were evaluated for use in deriving a cancer unit risk estimate (see Table 5-44). Ultimately, only the high confidence study by Beane Freeman et al. (2009) was advanced for POD derivation.

Table 5-44 Eligible epidemiology studies for POD derivation and rationale for decisions to not select specific studies for myeloid leukemia

Study,endpoint | Dose-response considerations (see Section 2.7) | | | | | Decision
Study,endpoint | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Residential Studies
Beane Freeman et al. (2009) Myeloid leukemia | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F); [+] Participation rate of cases (96%) and controls (94%) | [+] 2000 air samples; [+] Individuallevel continuous exposure; [+] Wide range (0.0–107.4 ppmyears); [+] Blinded to outcome | [+] Mortality: underlying cause from death certificates ICD-8: 205; [n] Incidence data not available | [n] N = 48 cases among 25,619 workers; [+] Poisson regression with slope parameters provided by Beane Freeman (Jinot and Beane-Freeman, 2014) | POD derived, limitation regarding results utility for doseresponse analysis noted.
Beane Freeman et al. (2009) Myeloid leukemia | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F); [+] Participation rate of cases (96%) and controls (94%) | [+] 2000 air samples; [+] Individuallevel continuous exposure; [+] Wide range (0.0–107.4 ppmyears); [+] Blinded to outcome | [+] Mortality: underlying cause from death certificates ICD-8: 205; [n] Incidence data not available | Some concern:; [-] No apparent association between myeloid leukemia mortality and cumulative exposure | POD derived, limitation regarding results utility for doseresponse analysis noted.
(Hauptmann et al., 2009) Myeloid leukemia; [Nested case-control study within extension of three embalmers cohorts described in Walrath and Fraumeni (1983, 1984); Hayes et al. (1990). | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F) | [+] Individual level, based on lifetime work practices and exposures to formaldehyde using a predictive model based on exposureassessment data; [+] Low levels and wide range (0 to >9253 pphrs; level = 0.01 ppm | [+] Mortality: underlying cause from death certificates ICD-8: 205 | [n] N = 34 cases out of 6,808 embalmers and funeral directors | No POD derived. Critical concern regarding results utility for doseresponse analysis in light of other available studies.
(Hauptmann et al., 2009) Myeloid leukemia; [Nested case-control study within extension of three embalmers cohorts described in Walrath and Fraumeni (1983, 1984); Hayes et al. (1990). | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F) | | [+] Mortality: underlying cause from death certificates ICD-8: 205 | Critical concern:; Significant trends of continuous metrics for duration and peak and significant categorical metric for cumulative exposure were not suitable for IUR. | No POD derived. Critical concern regarding results utility for doseresponse analysis in light of other available studies.
Meyers et al. (2013) Myeloid leukemia | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F) | [+] Individual level, based on lifetime work practices and exposures to formaldehyde using a predictive model based on exposure-assessment data; [+] Low levels and wide range (0 to >9253 pphrs; level = 0.01 ppm) | [+] Mortality: underlying cause from death certificates ICD-8: 205 | [n] N = 21 cases out of 11,043 garment workers | No POD derived. Critical concern regarding results utility for dose-response analysis.
Meyers et al. (2013) Myeloid leukemia | [+] High confidence; [+] Potential information bias unlikely; [+] Selection bias and confounding unlikely | [+] Diverse population (Adult M+F) | | [+] Mortality: underlying cause from death certificates ICD-8: 205 | Critical concern:; Multiple indications of increased risk with increased duration of exposure, but no cumulative exposure metric was reported. | No POD derived. Critical concern regarding results utility for dose-response analysis.
Coggon et al. (2014) Myeloid leukemia | [+] High confidence; [n] Potential information bias (latency not evaluated); [+] Selection bias and confounding unlikely | N/A | N/A | N/A | [n] N = 36 cases out of 14,008 garment workers | No POD derived. Critical concern regarding results utility for doseresponse analysis.
Coggon et al. (2014) Myeloid leukemia | [+] High confidence; [n] Potential information bias (latency not evaluated); [+] Selection bias and confounding unlikely | N/A | N/A | N/A | Critical concern:; No quantitative metrics of cumulative exposure. | No POD derived. Critical concern regarding results utility for doseresponse analysis.

N/A = not applicable = consideration was not influential to the decision (e.g., because a critical concern was identified).

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.9 for details).

Thus, similar to the unit risk estimate for NPC, the estimate for myeloid leukemia is based on results from the latest follow-up of the NCI cohort of industrial workers exposed to formaldehyde (Beane Freeman et al., 2009), the largest (25,619 workers) of the three independent industrial worker cohort studies and the only one with sufficient individual exposure data for dose-response modeling. Beane Freeman et al. (2009) conducted dose-response analyses of 123 deaths attributed to leukemia and leukemia subtypes, as well as deaths from other LHP malignancies. As previously described, this well-conducted study is the only one that used internal comparisons rather than standardized mortality ratios (reducing the impact of potential unmeasured confounding), and it included a detailed exposure assessment conducted for each worker based on exposure estimates for different jobs held and tasks performed (Stewart et al., 1986), and exposure estimates were made using several different metrics—peak exposure, average intensity, cumulative exposure, and duration of exposure.

For the LHP cancers, the strongest trends for the subtypes of interest were generally observed with the peak exposure metric (Beane Freeman et al., 2009). For myeloid leukemia, Beane Freeman et al. (2009) reported an increasing trend in mortality risk (p = 0.07 for all person-years) for peak exposure, but no trend was observed for cumulative exposure. For myeloid leukemia and other/unspecified leukemias combined, recognizing that a substantial proportion of the unspecified leukemias are probably myeloid leukemias, there was a nearly significant (log-linear) trend with cumulative exposure (p = 0.10 for all person-years) (personal communication from Laura Beane Freeman, NCI, to Jennifer Jinot, (Jinot and Beane-Freeman, 2014)). No exposure-response relationships were indicated for multiple myeloma for any of the exposure metrics.

##### Summary of Results from Exposure-response Modeling of the National Cancer Institute Cohort

The NCI cohort study (Beane Freeman et al., 2009), was the only study with adequate data for exposure-response modeling; however, the derivation of a unit risk estimate for myeloid leukemia from these data is not straightforward, and several quantitative risk assessment approaches were considered (see Appendix D.2.3).

In summary, EPA explored several approaches for deriving a unit risk estimate for myeloid leukemia based on cumulative exposure. The first approach involved using the grouping of leukemias classified as myeloid leukemia on the death certificate. The regression coefficient for this grouping had a p-value (0.44) indicative of a poor model fit. It was reasoned that the poor model fit could be due, at least in part, to the underreporting of myeloid leukemia deaths discussed above. As shown in Table 5-45, the regression coefficient for myeloid leukemia was only slightly lower than that for all leukemia, which had a lower p-value of 0.08 and should include all the myeloid leukemia deaths, both specified and unspecified. Thus, a second approach involved using the all leukemia grouping, which includes other subtypes likely not associated with formaldehyde exposure. Ultimately, the best available approach involved using the combined grouping of the myeloid leukemia and other/unspecified leukemias subcategories. The myeloid and other/unspecified leukemias grouping had a stronger association with cumulative exposure (p = 0.10) in the Beane Freeman et al. (2009) study than did myeloid leukemia alone and it captures the unclassified myeloid leukemias with the least inclusion of nonmyeloid leukemias. The benefits of focusing on the myeloid plus other/unspecified leukemias rather than the broader “all leukemia” grouping in attempting to be more inclusive of all the myeloid leukemias were deemed to outweigh any additional uncertainty associated with the background rates for the other/unspecified leukemias (discussed further below). The best available unit risk estimate for myeloid leukemia is the estimate of 4.2 × 10^−2^ per ppm (3.4 × 10^−2^ per mg/m^3^). Table 5-45 summarizes some of the key information comparing the different approaches attempted for different cancer groupings for the derivation of the unit risk estimate for myeloid leukemia, noting that the available estimates are all similar.

Table 5-45 Exposure-response modeling (all person-years) and (incidence) unit risk estimate derivation results for different leukemia groupings

Cancer grouping | Number of deaths in NCI cohort | Regression coefficient (per ppm × year) | SE (per ppm × year) | p-Value | Unit risk estimate (per ppm) | Unit risk estimate (per mg/m^3^)
Myeloid leukemia | 48 | 0.009908 | 0.01191 | 0.44 | 3.9 × 10^–2^ | 3.2 × 10^–2^
All leukemia | 123 | 0.01246 | 0.006421 | 0.08 | 5.9 × 10^–2^ | 4.8 × 10^–2^
Myeloid + Other/Unspecified leukemias | 84 ^a^ | 0.01408 | 0.007706 | 0.10 | 4.2 × 10^–2^ | 3.4 × 10^–2^

Note: Shaded estimate is considered the best available estimate.

a This is the sum of the leukemias classified as myeloid and those classified as “other/unspecified”. At least 70–80% of this number is expected to be myeloid leukemias, assuming that a third to a half of leukemias not otherwise specified on death certificates are myeloid leukemias, as discussed above.

##### Uncertainties and Confidence in the Best Available Unit Risk Estimate for Myeloid Leukemia

The strengths and uncertainties in the unit risk estimate for myeloid leukemia incidence are summarized in Table 5-46, with additional discussion in Appendix D.2.3. The primary uncertainty in this estimate relates to the complexities in the study-specific data for cumulative formaldehyde exposure and mortality from myeloid leukemia.

Table 5-46 Strengths and uncertainties in the cancer type-specific unit risk estimate for myeloid leukemia

Strengths | Uncertainties
- IUR estimated from data that is directly relevant to humans.; - Based on the results of a large, high confidence epidemiological study involving multiple industries with detailed, individual cumulative exposure estimates and allowance for cancer latency.; - Moderate number of deaths to model (N = 84). | Uncertainties with a potentially large impact:; ○ Although the dose-response relationship with peak exposure was marginally significant (p = 0.07), and statistically significant associations were reported for several metrics of exposure in other studies, the reported relationship with cumulative exposure showed a nonsignificant, small increase in risk for myeloid leukemia (based on the regression coefficient for the continuous model), potentially due in part to misclassification of myeloid leukemia cases.; ○ The association with cumulative exposure was stronger for the other/unspecified grouping of leukemia diagnoses (N = 36) than for myeloid leukemia alone (N = 48). Although a sizable proportion of this category is assumed to include myeloid leukemia cases, the stronger association is surprising given the more heterogeneous set of leukemia cases in this category, some presumably not associated with formaldehyde exposure. Hence, the association would be expected to be attenuated.; ○ Uncertainty about optimal exposure metric(s). Use of cumulative exposure assumes equal importance of concentration and duration on cancer incidence. The specific metrics analyzed differed across studies, and the results of the NCI study were not completely consistent with those of other studies (associated only with peak exposure).; Uncertainties likely to have a minor impact:; ○ Grouping of myeloid leukemias used for exposure-response modeling includes nonmyeloid leukemias.; ○ Borderline model fit for myeloid plus other/unspecified leukemias (p = 0.1) and uncertain shape of exposure-response function.

Based on the attendant strengths and uncertainties outlined above, there is low confidence in the unit risk estimate for myeloid leukemia incidence. However, given the strength of the evidence integration judgment (i.e., evidence demonstrates formaldehyde inhalation causes myeloid leukemia in humans), and the associated public health burden that it poses (e.g., myeloid leukemia is far more prevalent than NPC), EPA thoroughly considered the complexity in the data and attempted an innovative approach to derive a potential unit risk estimate for myeloid leukemia. However, the uncertainty in this value was ultimately considered too great and the best available unit risk estimate for myeloid leukemia was not used to inform the quantification of risk for cancer. The uncertainty associated with being unable to address myeloid leukemia in the IUR is discussed further below.

#### Derivation of LHP Cancer Unit Risk Estimates Using Animal Data

##### Choice of Animal Studies

The available high and medium confidence experimental animal studies of LHP cancers were evaluated for use in deriving a cancer unit risk estimate (see Table 5-47). As described for hazard identification (Section 3.3.3), the evaluation focused on advancing long-term studies with detailed evaluations of tissues relevant to LHP cancers. Subchronic and shorter duration studies were not considered. Thus, the two low confidence studies included in the synthesis evaluation of LHP cancers that evaluated chronic formaldehyde exposure in rats (Sellakumar et al., 1985) and 8-week formaldehyde exposure in genetically modified (p53 +/-) mice (Morgan et al., 2017) were not considered for use in dose-response analyses. Based on the evaluation presented in Table 5-47, a unit risk estimate for myeloid leukemia based on evaluations of LHP cancers was not derived from the available animal data.

Table 5-47 Eligible experimental animal studies for POD derivation and rationale for decisions to not select specific studies for LHP cancers

Study, species | Dose-response considerations (see Section 2.7) | | | | | Decision
Study, species | Study evaluation^a^ | Population or subjects | Exposure | Outcome measure(s) | Result(s) utility | Decision
Rat Studies
(Kerns et al., 1983); (Battelle, 1982); F344 rats (M+F) | [n] Medium confidence; [+] Good exposure quality | [n] Despite different LHP physiology, rats are considered reasonably appropriate models | [+] 2-year exposure; [+] Broad exposure range | Critical concern:; [--] Slide evaluation only for highest exposure group unless gross lesions present | [+] Large N (N = 119-121) [n] Lack of blinding for tumor analyses not a significant limitation. | No POD derived. Critical outcome measure and results utility (for dose-response) concerns.
(Kerns et al., 1983); (Battelle, 1982); F344 rats (M+F) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] High mortality at highest formaldehyde levels | [+] 2-year exposure; [+] Broad exposure range | Critical concern:; [--] Slide evaluation only for highest exposure group unless gross lesions present | Critical concern:; [--] Lesion incidence not available for all exposure levels; [--] No clear LHP cancer increases (note: bone marrow hyperplasia significantly increased) | No POD derived. Critical outcome measure and results utility (for dose-response) concerns.
Kamata et al. (1997);; F344 rats (M) | [n] Medium confidence; [n] Adequate exposure quality | [n] Despite different LHP physiology, rats are considered reasonably appropriate models | [+] > 2-year exposure; [+] Broad exposure range | Critical concern:; [--] Slides evaluation only for nasal tissues unless gross lesions present | [n] Adequate N; (N = 32) [n] Lack of blinding for tumor analyses not a significant limitation | No POD derived. Critical outcome measure and results utility (for doseresponse) concerns.
Kamata et al. (1997);; F344 rats (M) | [n] Medium confidence; [n] Adequate exposure quality | Some concern:; [-] Males only | Some concern:; [-] Use of formalin as test article (even with a methanol control group) introduces some quantitative uncertainty | Critical concern:; [--] Slides evaluation only for nasal tissues unless gross lesions present | Critical concern:; [--] LHP lesion incidence not reported; [--] Author-reported no increased LHP cancer incidence | No POD derived. Critical outcome measure and results utility (for doseresponse) concerns.
Mouse Studies
Kerns et al. (1983), Battelle (1982); B6C3F1 Mice (M+F) | [n] Medium confidence; [+] Good exposure quality | [n] Despite different LHP physiology, mice are considered reasonably appropriate models | [+] 2-year exposure; [+] Broad exposure range | Critical concern:; [--] Slide evaluation only for highest exposure group unless gross lesions present. | [+] Large N (N = 119-121); [n] Lack of blinding for tumor analyses not a significant limitation | No POD derived. Critical outcome measure and results utility (for dose-response) concerns.
Kerns et al. (1983), Battelle (1982); B6C3F1 Mice (M+F) | [n] Medium confidence; [+] Good exposure quality | Some concern:; [-] Survival to 18 mo. < 33% in exposed males | [+] 2-year exposure; [+] Broad exposure range | Critical concern:; [--] Slide evaluation only for highest exposure group unless gross lesions present. | Critical concern:; [--] Lesion incidence not available for all exposures; [--] No clear LHP cancer increases (note: lymphomas were elevated in female mice at 15 ppm [27/121] as compared to controls [19/121], but not statistically significantly) | No POD derived. Critical outcome measure and results utility (for dose-response) concerns.

a Select features of the study evaluations that may have the most impact on quantification may be highlighted (if not otherwise highlighted in other columns), but the bullets in this column do not represent a full synopsis (see Appendix B.3.9 for details).

#### Summary of Unit risk Estimation for Myeloid Leukemia

No unit risk estimates with adequate certainty were derived.

### 5.2.3 Selection of Unit Risk Estimate(s) for Derivation of the Inhalation Unit Risk

Table 5-48 Summary of unit risk estimates

Basis | Unit risk estimate (per ppm) | | Unit risk estimate (per mg/m^3^)
Nasopharyngeal cancer in humans^a^ | 4.5 × 10^−3^; (mortality-based) | 9.1 × 10^−3^; (incidence-based) | 3.7 × 10^−3^; (mortality-based) | 7.4 × 10^−3^; (incidence-based)
Animal nasal cancer estimate^b^ | 1.1 × 10^−2^ to 2.2 × 10^−2^ | | 8.9 × 10^−3^ to 1.8 × 10^−2^

a Based on entire cohort (exposed and unexposed) from Beane Freeman et al. (2013).

b Based on modeling of tumor incidence in rats incorporating results from multiple mechanistic and statistical models, including BBDR modeling (Monticello et al., 1996; Kerns et al., 1983). Range covers only the human extrapolations based on internal doses and BMR’s ≤ 0.01 extra risk levels.

The unit risk estimate for NPC derived using data from the NCI occupational cohort and the nasal cancer unit risk estimate based on squamous cell carcinomas in animals are summarized in Table 5-48. As discussed previously, the NPC unit risk estimate based on data from the human occupational epidemiology study of the NCI updated by Beane Freeman et al. (2013) was selected over-estimates based on rodent cancer bioassay data, although these estimates were very similar (see more detailed comparison in Table 5-42). As described in prior sections, data were not available to quantify the potential risk for development of sinonasal cancers and the best available unit risk estimate for myeloid leukemia was considered too uncertain. Thus, the unadjusted unit risk estimate used for the IUR is 7.4 × 10^−6^ per µg/m^3^ (7.4 × 10^−3^ per mg/m^3^) based on human NPC incidence.

### 5.2.4 Adjustment for Potential Increased Early-life Susceptibility

When there is sufficient weight of evidence to conclude that a mutagenic MOA is operative in a chemical’s carcinogenicity and there are inadequate chemical-specific data to assess age-specific susceptibility, as is the case for formaldehyde inhalation exposure-induced NPCs (see Section 3.2.5), EPA guidelines (U.S. EPA, 2005b) recommend the application of default age-dependent adjustment factors (ADAFs) to adjust for potential increased susceptibility from early-life exposure. In brief, the supplemental guidelines established ADAFs for three specific age groups. The current ADAFs and their age groupings are 10 for <2 years, 3 for 2 to <16 years, and 1 for 16 years and above (U.S. EPA, 2005b). For risk assessments based on specific exposure assessments, the 10-fold and three-fold adjustments to the unit risk estimates are to be combined with age-specific exposure estimates when estimating cancer risks from early-life (<16 years of age) exposure.

These ADAFs were formulated based on comparisons of the ratios of cancer potency estimates from juvenile-only exposures to cancer potency estimates from adult-only exposures from rodent bioassay data sets with appropriate exposure scenarios, and they are designed to be applied to cancer potency estimates derived from adult-only exposures. Thus, alternate life-table analyses were conducted for NPC to derive comparable adult-based unit risk estimates to which ADAFs would be applied to account for early-life exposure. In the NCI Poisson regression model, the RR estimates are adjusted for age, for the ages represented in the cohort. In deriving lifetime unit risk estimates, EPA generally extrapolates that relationship and assumes that RR is independent of age for all ages, for application of the RR exposure-response model across the full age range (0–85 years) considered in the life-table analysis. For the alternate life-table analyses, it was assumed that RR is independent of age for adults, which represent the lifestage for which the exposure-response data and the Poisson regression modeling results from the NCI cohort study specifically pertain, but that there is increased early-life susceptibility, based on the weight of evidence-based conclusion that formaldehyde carcinogenicity for NPC has a mutagenic MOA (see Section 3.2.5), which supersedes the more general assumption that RR is independent of age for all ages including children.

In the alternate analyses, exposure in the lifetable was taken to start at age 16 years, the age cut-point that was established in EPA’s supplemental guidelines (U.S. EPA, 2005b), to derive an adult-exposure-only unit risk estimate. The adult-exposure-only unit risk estimate, when rescaled as described below, yields an adult-based unit risk estimate that is comparable to the unit risk estimate calculated from a typical (i.e., with adult exposures only) rodent bioassay and to which ADAFs can be applied in the standard way to account for early-life exposure.^71^ Other than the age at which exposure was initiated, the life-table analysis is identical to that conducted for the results presented in Section 5.2.1. Using this approach yields adult-exposure-only unit risk estimates of 3.15 × 10^−3^ per ppm (2.56 × 10^−6^ per μg/m^3^) for NPC mortality and 6.09 × 10^−3^ per ppm (4.95 × 10^−6^ per μg/m^3^) for NPC incidence; these results are about 70 and 67%, respectively, of the unit risk estimates derived for lifetime exposure under the assumption of age independence across all ages.

When EPA derives unit risk estimates from standard rodent bioassay data, there is a blurring of the distinction between lifetime and adult-only exposures because the relative amount of time that a rodent spends as a juvenile is negligible (e.g., 9 of 104 weeks <9%) compared to its lifespan. [According to the supplemental guidelines, puberty begins around 5–7 weeks of age in rats and around 4–6 weeks in mice (U.S. EPA, 2005b), and Sengupta (2013) suggests that adulthood in rats typically begins around postnatal day 63.] Thus, when exposure in a rodent is initiated at 5–8 weeks (most of the way through the juvenile period), as in the standard rodent bioassay, and the bioassay is terminated after 104 weeks of exposure, the unit risk estimate derived from the resulting cancer incidence data is considered a unit risk estimate from lifetime exposure, except when the ADAFs were formulated and are applied, in which case the same estimate is considered to reflect adult-only exposure. Yet, when adult exposures are considered in the application of ADAFs, the adult-exposure-only unit risk estimate is pro-rated over the full default human lifespan of 70 years, presumably because that is how adult exposures are treated when a unit risk estimate calculated in the same manner from the same bioassay exposure paradigm is taken as a lifetime unit risk estimate.

However, in humans, a greater proportion of time is spent in childhood (e.g., 16 of 70 years = 23%) (and for the purposes of unit risk estimates, exposure is considered to commence at birth), and the distinction between lifetime exposure and adult-only exposure cannot be ignored when human data are used as the basis for the unit risk estimates. Thus, adult-exposure-only unit risk estimates were calculated distinct from the lifetime estimates that were derived in Section 5.2.1 under the assumption of age independence for all ages. In calculating the adult-exposure-only unit risk estimates, RR is assumed to be independent of age for adulthood. Next, the adult-exposure-only unit risk estimates need to be rescaled to a 70-year lifespan to be used in the ADAF calculations and risk estimate calculations involving less-than-lifetime exposure scenarios in the standard manner, which includes pro-rating even adult-based unit risk estimates over 70 years. Thus, the adult-exposure-only unit risk estimates are multiplied by 70/54 to rescale the 54-year adult period of the 70-year default lifespan to 70 years. Then, for example, if a risk estimate were calculated for a less-than-lifetime exposure scenario involving exposure only for the full adult period of 54 years, the rescaled unit risk estimate would be multiplied by 54/70 in the standard calculation and the adult-exposure-only unit risk estimate would be appropriately reproduced. Without rescaling the adult-exposure-only unit risk estimates, the example calculation just described for exposure only for the full adult period of 54 years would result in a risk estimate 77% (i.e., 54/70) of that obtained directly from the adult-exposure-only unit risk estimates, which would be illogical. The rescaled adult-based unit risk estimates for NPC mortality and incidence for use in ADAF calculations and risk estimate calculations involving less-than-lifetime exposure scenarios are presented in Table 5-49.

Table 5-49 Adult-based unit risk estimates for nasopharyngeal cancer for use in ADAF calculations and risk estimate calculations involving less-than-lifetime exposure scenarios

NPC response | Adult-based unit risk estimate
NPC response | (per ppm) | (per μg/m^3^)
Mortality | 4.08 × 10^−3^ | 3.31 × 10^−6^
Incidence | 7.90 × 10^−3^ | 6.42 × 10^−6^

An example calculation illustrating the application of the ADAFs to the human-data-derived adult-based (rescaled as discussed above) NPC (incidence) unit risk estimate for formaldehyde for a lifetime exposure scenario is presented below. For inhalation exposures, assuming ppm equivalence across age groups, i.e., equivalent risk from equivalent exposure levels, independent of body size, the ADAF calculation is fairly straightforward. Thus, the ADAF-adjusted lifetime NPC unit risk estimate is calculated as illustrated in Table 5-50.

Table 5-50 NPC incidence risk from exposure to constant formaldehyde exposure level of 1 μg/m^3^ from ages 0 to 70 years

Age group | ADAF | Adult-Based Unit risk (perμg/m^3^) | Concentration (μg/m^3^) | Duration adjustment | Partial risk^a^
0 to <2 years | 10 | 6.42 × 10^−6^ | 1 | 2 year/70 year | 1.83 × 10^−6^
2 to <16 years | 3 | 6.42 × 10^−6^ | 1 | 14 year/70 year | 3.85 × 10^−6^
≥16 years | 1 | 6.42 × 10^−6^ | 1 | 54 year/70 year | 4.95 × 10^−6^
Total Lifetime (70 year) Risk: 1.06 × 10^−5^

a The partial risk for each age group is the product of the values in columns 2–5 [e.g., 10 × (6.42 × 10^−6^) × 1 × 2/70 = 1.83 × 10^−6^], and the total risk is the sum of the partial risks.

This 70-year risk estimate for a constant exposure of 1 μg/m^3^ is equivalent to a lifetime inhalation unit risk (IUR) of 1.1 × 10^−5^ per μg/m^3^ (1.3 × 10^−2^ per ppm) based on NPC incidence, adjusted for potential increased early-life susceptibility, assuming a 70-year lifetime and constant exposure across age groups. Note that because of the use of the rescaled adult-based unit risk estimate, the partial risk for the ≥16 years’ age group is the same as would be obtained for a 1 μg/m^3^ constant exposure directly from the adult-exposure-only unit risk estimate of 4.95 × 10^−6^ per μg/m^3^ that was presented above, as it should be. Recall that the adult exposure-only based unit risk estimate for NPC incidence for use in ADAF calculations and risk estimate calculations involving less-than-lifetime exposure scenarios is 6.42 × 10^−6^ per μg/m^3^ (7.90 × 10^−3^ per ppm).

In addition to the uncertainties discussed in Section 5.2.1 for the IUR estimates based on human data, there are uncertainties in the application of ADAFs to adjust for potential increased early-life susceptibility. The ADAFs reflect an expectation of increased risk from early-life exposure to carcinogens with a mutagenic MOA (U.S. EPA, 2005b), but they are general adjustment factors and are not specific to formaldehyde. Overall, the application of ADAFs to the NPC unit risk estimate could be overestimating or underestimating the true extent of any increased early-life susceptibility in the total cancer unit risk estimate, although the quantitative impact of this source of uncertainty is likely to be small.

### 5.2.5 Final Inhalation Unit Risk Estimate and Uncertainties

The IUR, summarized in Table 5-51, reflects the estimate for NPC incidence alone. The NPC unit risk estimates are based on the modeling results of the association of cumulative formaldehyde exposure with NPC mortality in an occupational cohort followed by the NCI (Beane Freeman et al., 2013). The regression coefficient from the exposure-response model (log-linear Poisson regression model) was applied to age-specific cancer incidence rates from the SEER database using life-table methods to estimate the POD from which to derive the (upper-bound) unit risk estimate. The IUR estimate is typically expressed as the (upper-bound) increase in cancer risk expected as a function of a change of 1 µg/m^3^.

EPA has concluded that early-life exposure to chemicals that are carcinogenic through a mutagenic MOA might present a higher risk of cancer than exposure during adulthood (U.S. EPA, 2005b). In this document, it was determined that formaldehyde-induced carcinogenicity of the URT is attributable, at least in part, to a mutagenic MOA (see Section 3.2.5). Therefore, the cancer unit risk estimate was adjusted by applying age-dependent adjustment factors (ADAFs). Table 5-51 can be used as a template for incorporating the ADAFs when addressing less-than-lifetime exposure scenarios. For exposure scenarios comprising primarily adult exposures, it may not be worth the additional complexity of calculating the ADAF-adjusted risk estimates, and one may choose to use the unadjusted cancer unit risk estimate presented in Table 5-51 with a “c” superscript, to calculate risk estimates in the standard way (i.e., without application of ADAFs).

Table 5-51 Inhalation unit risk^a,^ ^b^

Cancer type | Unit risk estimate; (ppm^−1^) | ADAF-adjusted unit risk estimate; (ppm^−1^) | Unit risk estimate; ((µg/m^3^)^−1^) | ADAF-adjusted unit risk estimate; ((µg/m^3^)^−1^)
Nasopharyngeal | 0.0079^c^ | 0.013 | 6.4 × 10^−6c^ | 1.1 × 10^−5^

a The inhalation unit risk estimate is typically expressed as the (upper-bound) increase in cancer risk estimated for an exposure increase of 1 µg/m^3^.

b The unit risk estimate is for cancer incidence.

c Adult-based (rescaled) unit risk estimate for NPC intended for the application of ADAFs.

#### Benchmark Response /Effective Concentration Estimates

For benefits analyses and certain other situations, “central” estimates of risk-per-unit dose may be preferred over (upper-bound) unit risk estimates. For nonlinear models, the POD-approach used by EPA for low-dose extrapolation, which is designed to distinguish between dose-response modeling in the observable range and inferences made about lower doses (U.S. EPA, 2005a) is not amenable to providing central estimates of risk at lower doses. Instead, the standard practice for IRIS assessments is to provide linear extrapolations of risk from the central estimate (here, the effective concentration [EC] estimate, which is the MLE of the exposure concentration associated with the benchmark response level of risk) corresponding to the POD, which is the lower bound on the EC (i.e., the LEC estimate). Table 5-52 presents estimates of risk-per-unit dose linearly extrapolated from the EC (i.e., BMR/EC estimates).

Table 5-52 Summary of BMR/EC estimates^a^

Cancer type | BMR/EC estimate; (ppm^−1^) | ADAF-adjusted BMR/EC estimate^b^; (ppm^−1^) | BMR/EC estimate; ((µg/m^3^)^−1^) | ADAF-adjusted BMR/EC estimate^b^; ((µg/m^3^)^−1^)
Nasopharyngeal | 0.0046^c^ | 0.0076 | 3.7 × 10^−6c^ | 6.2 × 10^−6^

a The BMR/EC estimates based on a longitudinal occupational mortality study (Beane Freeman et al., 2013) are all for cancer incidence. The BMR is 0.0005 extra risk for NPC. The EC value is the exposure concentration associated with the BMR based on the Poisson regression model and life-table analysis (see Section 5.2.1). The EC_0005_ for NPC was calculated from a life-table analysis of adult-exposure-only and then rescaled as discussed for the adult-based unit risk estimates in Section 5.2.4.

b See Section 5.2.4 for a discussion of the ADAF adjustments and how to apply the ADAFs for less-than-lifetime exposure scenarios.

c Adult-based (rescaled) BMR/EC estimate for NPC intended for the application of ADAFs (see Sectionn5.2.4).

#### Sources of Uncertainty Associated with the Inhalation Unit Risk

In general, the major areas of uncertainty in unit risk estimates arise from limitations in the database, e.g., limitations resulting in the need for interspecies and high- to low-dose extrapolation and limitations in information on human variability, including especially sensitive populations. The ideal database would provide sufficient data for the direct calculation of robust cancer (incidence) estimates for the general population at environmental levels of exposure.

The availability of suitable human data from which to derive unit risk estimates eliminates one of the major sources of uncertainty inherent in most unit risk estimates—the uncertainty associated with interspecies extrapolation. The NCI study used as the basis for the selected unit risk estimate is considered a well-conducted study for the purposes of deriving unit risk estimates. The NCI study is a large longitudinal cohort study that developed individual worker exposure estimates using detailed employment histories and formaldehyde concentration measurements. In addition to the detailed exposure assessment, the study used internal analyses and carefully considered potential confounding or modifying variables. Moreover, the NCI study comprises a large cohort that has been followed for a long time. Nonetheless, uncertainties in derived unit risk estimates are inevitable. The sources of uncertainty related to these limitations include use of a single study to derive the unit risk estimate, the inability to derive unit risk estimates for all potential cancer sites, and the derivation of (incidence) unit risk estimates for the general population from an occupational mortality study.

Overall confidence in the selected unit risk estimate is medium. Although some uncertainty exists with respect to the low-exposure extrapolation, the estimate is based on human data on NPC from a large, high-quality epidemiological study. Furthermore, the estimate is similar to the estimate derived for nasal cancers from rodent data. Notably, the IUR is an underestimate due to the inability to quantitatively incorporate the risks posed for sinonasal cancers and myeloid leukemia.

##### Use of a single study to derive unit risk

A major limitation in the human database for formaldehyde is that there was only one independent^72^ epidemiology study, the NCI study (Beane Freeman et al., 2009; Beane Freeman et al., 2013), with adequate exposure estimates for the derivation of unit risk estimates, as discussed above. Although the unit risk estimation from human data used data from one epidemiological study, it is a large longitudinal cohort study that included workers from 10 different industrial plants, in different states, that produced or used formaldehyde in different products. These factors decrease the likelihood that the results are overly influenced by uncontrolled confounding related to either location or production process. The NCI study developed individual worker exposure estimates using detailed employment histories and formaldehyde concentration measurements. In addition to the detailed exposure assessment, the study used internal comparisons of risk from exposure and gave careful consideration to potential confounding or modifying variables. Thus, although the unit risk estimates are based on a single study, there is high confidence in that study.

##### Inability to derive unit risk estimates for all potential cancer sites

The IUR is based on results for NPC from the NCI study; however, the NCI study did not support the computation of unit risk estimates for all the cancer sites with an evidence integration judgment of evidence demonstrates based on the totality of the evidence (i.e., sinonasal cancer and myeloid leukemia risk are unaddressed by the IUR), and the contribution by these cancers to the total cancer risk associated with formaldehyde inhalation is unknown. However, the potential impact by myeloid leukemia suggested by the best available unit risk estimate (myeloid leukemia plus other/unspecified leukemia) might increase the ADAF-adjusted IUR by almost four-fold.

##### Derivation of incidence estimates from mortality data

The NCI study is a retrospective mortality study, and cancer incidence data are unavailable for the cohort. Using mortality risk would markedly underestimate incidence for NPC because survival for this cancer type is relatively high. This limitation was addressed quantitatively in the calculation of cancer incidence risk estimates using the dose-response relationships from the mortality study, although as discussed above, it was necessary to make certain assumptions. It was assumed that cancer incidence and mortality have the same exposure-response relationship for formaldehyde exposure, which is reasonable for NPC at the low induction rates observed. Despite the uncertainties introduced, the incidence-based estimates are believed to be better estimates of cancer incidence risk than the mortality-based estimates, given the high survival rates for these cancers. The estimates may under- or overpredict the true risk, although the quantitative impact would be relatively low because the incidence estimates are constrained by the relative incidence: mortality rates and necessarily bounded by the mortality estimates, which are about 50% of the incidence estimates.

##### Generalizability of estimates from a worker population

The NCI data represent an industrial worker cohort that is generally healthier than the U.S. population at large. Therefore, the unit risk estimates derived from the NCI worker cohort data could underestimate the cancer risk for the general population to an unknown extent, although the impact is expected to be relatively low for the majority of the population.

Industrial workers can also differ from the general population in factors other than health status. In terms of representing the general population in other ways, the NCI cohort was somewhat diverse, but the workers were predominantly white males (81%), then white females (12%), black males (7%), and black females (<1%), and they were all adults. Thus, for example, cancer risk in the general population could be underestimated if females are more susceptible than males, or overestimated if males are more susceptible than females. The potential for increased early-life susceptibility is addressed explicitly in Section 5.2.4.

##### High- to low-dose extrapolation

The availability of human data from this occupational epidemiology study for the derivation of quantitative cancer risk estimates removes the need to extrapolate from the findings of rodent bioassays, a major source of uncertainty in most risk assessments. However, another major source of uncertainty inherent in most unit risk estimates remains—the uncertainty associated with extrapolation from high (in this case occupational) exposures to lower (environmental or typical nonoccupational indoor) exposures. One factor contributing to uncertainty in the low dose-response comes from the potential for endogenous formaldehyde levels in respiratory tissue to reduce the uptake of the inhaled gas at low doses, as demonstrated in modeling efforts by Schroeter et al. (2014) and Campbell Jr et al. (2020). This would be expected to result in an overprediction of the true risk.

Although the actual exposure-response relationship at low-exposure levels is unknown, the use of linear low-dose extrapolation is supported by evidence that formaldehyde has a mutagenic MOA for NPC. The linear low-dose extrapolation from the 95% lower bound on the exposure level associated with the extra risk level serving as the benchmark response is considered to be a plausible upper bound on the risk at lower exposure levels. Use of the upper bound is a health-protective practice recommended in EPA guidelines (U.S. EPA, 2005a).

#### Additional Sources of Uncertainty Stemming from the NCI Study and Its Analysis

Other sources of uncertainty arise from the key epidemiological study and its analysis (Beane Freeman et al., 2013), including the retrospective estimation of formaldehyde exposures in the cohort, the modeling of the epidemiological exposure-response data, the exposure metric for exposure-response analysis, and potential confounding or modifying factors.

##### Exposure estimates

With respect to exposure estimation, the NCI investigators (Stewart et al., 1986) conducted a detailed retrospective exposure assessment to estimate the individual worker exposures. Formaldehyde exposures were estimated for specific jobs/tasks based on monitoring data, discussions with workers and plant managers, and assessment by industrial hygienists. Individual worker estimates were derived for a variety of exposure metrics based on work histories. This exposure assessment was a major undertaking, involving over 100 person-months. Hauptmann et al. (2004) suggested that employment of such a detailed exposure assessment would tend to minimize exposure misclassification for average and cumulative exposure and duration of exposure but that peak exposure estimates could be more susceptible to misclassification because they were defined more qualitatively. In addition, the follow-up study did not account for exposures after 1980. Beane Freeman et al. (2013) suggest that any underestimation of total exposure resulting from the 1980 cutoff would be small because only 3.5% of all person-years were contributed by workers who were 65 years or younger and in exposed jobs in 1980 and because exposure levels were believed to have been much lower after 1980 than in earlier years.

Marsh et al. (1996) also estimated individual worker exposures at one of the 10 plants (Wallingford, Connecticut) studied by the NCI team. The Marsh et al. (1996) exposure estimates were about 10-fold lower than those derived by the NCI for the workers at the Wallingford plant. Marsh et al. (2002) hypothesized that “the NCI used data from several facilities to estimate exposures in a single facility.” However, the NCI investigators maintain that they estimated exposures for each plant separately. While the exact reasons for such a large discrepancy are unclear, some differences in the assessment procedures which could have resulted in substantial differences in the estimates are apparent. First, according to Marsh et al. (1996), 91.7% of the white male Wallingford plant workers were specified as being exposed to formaldehyde in the NCI study, while only 83.3% were considered to have been exposed in the Marsh et al. (1996) analysis (it should be noted that these two cohorts of the Wallingford plant are not identical). Second, the NCI investigators (Stewart et al., 1986; Stewart et al., 1987) did their own exposure monitoring at all the plants, including the Wallingford facility, to standardize the data provided by the plants as well as to fill data gaps for certain jobs. There is no indication that Marsh et al. (1996) made any additional measurements themselves. Third, although the (Marsh et al., 1996; Marsh et al., 2002) papers are not entirely consistent on this point, those investigators apparently assumed that the job-specific exposures at the plant were essentially constant over the history of the plant, whereas the NCI team, based on interviews with plant personnel knowledgeable about equipment and process changes, assumed that past exposures were higher.

In any event, despite the discrepancies in the absolute exposure values, the relative exposures for both the (Marsh et al., 1996; Marsh et al., 2002) and NCI studies, as reflected in the exposure-response relationships, are less subject to misclassification and are considered to be reliable. The Wallingford plant is just one of the 10 plants in the NCI study (representing 4,389 of the 25,619 workers in the NCI cohort), but if the Marsh et al. (1996) exposure estimates, which are roughly 10-fold lower than the NCI estimates, are closer to the actual exposures for those workers, then the true potency of formaldehyde could be greater than that suggested by the unit risk estimates calculated above based on the NCI data. Furthermore, if the NCI exposure values were significantly overestimated across all 10 plants, then the actual potency could be higher still.

In summary, EPA has high confidence in the NCI exposure assessment because of the large effort and high degree of expertise that NCI devoted to developing their detailed exposure estimates. Nonetheless, errors in retrospective exposure assignments are inevitable, and as a result, the unit risk estimates based on the NCI study could overpredict or underpredict the true risks to an unknown extent, although the discrepancy with the independently derived Marsh et al. (1996) exposure estimates suggests that the risks might be underestimated.

###### Exposure-response modeling

With respect to the exposure-response model, the log-linear Poisson regression model used by the investigators (Beane Freeman et al., 2009; Beane Freeman et al., 2013) for their trend tests (i.e., RR = e^βX^) is generally an appropriate model for the analyses of epidemiological cancer data.^73^ As discussed above, when age is well characterized and adjusted for, as it was in the NCI study, the results of the Poisson regression model should be essentially the same as results from the Cox proportional hazards model (Callas et al., 1998). The investigators reported efforts to check for deviations from log-linearity by adding a quadratic term to their models; none of these additional terms was statistically significant. However, the “true” underlying exposure-response relationships are unknown.

Even if the correct exposure-response model for NPC was known, there would be substantial uncertainty in estimating the model parameters because there are only 10 NPC deaths to model. Additionally, a 15-year lag was used for all the NCI solid cancer models. The actual best lag interval is unknown; the NCI investigators reported that lag intervals between 2 and 20 years yielded similar results.

###### Exposure metrics

Another potentially significant source of uncertainty is associated with the exposure metrics. With the log-linear model used for modeling the occupational data, the peak exposure metric gave the strongest exposure-response relationship between formaldehyde exposure and increased risk of NPCs. However, as discussed above, there are limitations in the peak exposure metric, and it is unclear how to extrapolate RR estimates based on peak exposure estimates to meaningful estimates of lifetime extra risk of cancer from environmental exposure (i.e., extra risk from lifetime continuous low-level environmental exposures). The cumulative exposure metric also yielded nearly statistically significant exposure-response relationships (p = 0.07) and was used for the cancer risk calculations in this assessment. The “true” exposure metric best describing the toxicologically relevant dose of formaldehyde for carcinogenesis is unknown. If a peak-exposure type of metric is the best representative of the toxicologically relevant dose, this suggests that there are dose-rate effects in the exposure-response relationship for formaldehyde and cancer. If this is the case, the unit risk estimates presented here, which are based on a linear low-dose extrapolation, could overpredict the true risks.

###### Influence of confounding or effect modification

Beane Freeman et al. (2013) provided a detailed description of their evaluation of potential confounding and modifying factors in their analyses. The important factors of age, race, sex, calendar year, and pay category were taken into account in the Poisson regression and trend analyses. Furthermore, they used the low-exposure person-years, rather than the unexposed person-years, as their referent group to minimize any potential confounding effects resulting from differences in socioeconomic or other characteristics between exposed and unexposed workers. When the slope estimate (i.e., regression coefficient) for the exposed person-years only was used in the analyses, the unit risk estimate was essentially identical to that calculated from the slope estimate for all person-years (see Section 5.2.1).

In addition, these investigators evaluated routine respirator use, exposure to formaldehyde-containing particulates, durations of exposure to 11 other chemicals/substances in the plants (antioxidants, asbestos, carbon black, dyes and pigments, hexamethylenetetramine, melamine, phenol, plasticizers, urea, wood dust, and benzene), and duration of employment as a chemist or laboratory technician. Only 133 workers ever routinely used a respirator (Hauptmann et al., 2003). RR estimates reportedly did not change substantially when adjusted for exposure to any of the other 10 chemicals/substances in the NPC (with cumulative exposure) analyses (Beane Freeman et al., 2013). Only one of the workers who died of NPC was identified as being exposed to wood dust, a recognized nasopharynx carcinogen. Adjusting for duration of time spent working as a chemist or laboratory technician did not substantially alter the results for NPC (Beane Freeman et al., 2013).

Beane Freeman et al. (2013) reported that their analyses showed no evidence of plant heterogeneity for the solid tumor results. In addition, six of the 10 deaths with NPC on the death certificate were from the Wallingford plant also studied by Marsh et al. (2007b).^74^ Marsh et al. (2007a) hypothesized that the excess NPCs in the Wallingford plant could be due to external employment in metal-working industries. However, as noted by Beane Freeman et al. (2013), when Marsh et al. (2007a) adjusted for metal-working, the associations of NPC with formaldehyde for different metrics of exposure did not decrease.

Although smoking data were not available for the cohort, smoking is unlikely to explain the excesses in NPCs because there was no consistent increase for tobacco-related diseases, including lung cancer, across the same exposure metrics. No information was available on Epstein-Barr virus infections, a major risk factor for NPC, in the cohort.

In the reporting of the previous follow-up, Hauptmann et al. (2004) noted that each of the seven formaldehyde-exposed workers who had died of NPC was also exposed to particulates and neither of the two workers who died of NPC but were not exposed to formaldehyde was exposed to particulates. Due to the complete collinearity of formaldehyde and particulate exposures, one cannot estimate the exposure-response slope in workers exposed only to formaldehyde. The exposure-response relationships observed for formaldehyde within the NCI cohort and the associations observed between formaldehyde exposure and NPC in workers not exposed to particulates indicate that there is a formaldehyde effect independent of particulates; however, one cannot rule out a possible modifying effect of particulates, which might, for example, enhance delivery of formaldehyde to the nasopharynx.

In summary, uncontrolled confounding could theoretically result in unit risk estimates that are either under- or overestimated; nevertheless, given the careful consideration paid to potential confounding, any quantitative impacts are expected to be minimal. However, a possible modifying effect of particulate exposure on NPC cannot be ruled out, which could overestimate the risk from formaldehyde alone to an unknown extent.

###### Perspective on uncertainty in extrapolation using background cancer incidence and internal dose of endogenous and exogenous formaldehyde

EPA has considered estimates derived by Swenberg et al. (2011) and Starr and Swenberg (Starr and Swenberg, 2016) that are referred to by the authors as a “bottom-up” approach, to bound low-dose human cancer risks from formaldehyde exposure in a manner that only uses information regarding background incidence in the U.S. population of nasopharyngeal cancers (NPC), leukemia, and Hodgkin lymphoma; background (endogenous) metrics of internal formaldehyde dose in laboratory animals; and exogenous exposure to formaldehyde expressed in terms of an internal dose. The results in Starr and Swenberg (Starr and Swenberg, 2016) are updates, based on newer data, to those presented earlier in (Starr and Swenberg, 2013); however, the approach remains unchanged.

The data for the internal dose in these calculations were obtained from measurements in rats and monkeys of formaldehyde-induced DNA adducts experiments based on a highly sensitive mass spectrometry (MS) method using [^13^CD_2_]-formaldehyde (Yu et al., 2015a; Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011). The authors of these experiments conclude that their method can be used to distinguish whether formaldehyde-induced hydroxymethyl-DNA monoadducts, in particular the N^2^-hydroxymethyl-dG (N2-hmdG) adduct, originate from endogenous or exogenous sources of formaldehyde. The experiments quantified this mono adducts formed from both sources in various tissues of rats and monkeys: nasal cavity, bone marrow, mononuclear WBCs, spleen, and thymus (rats); nasal cavity and bone marrow (monkeys). These adduct measurements and data on the background incidences of NPC, Hodgkin lymphoma, and leukemia in the U.S. population were then used (Starr and Swenberg, 2016) to develop cancer risk estimates by attributing all the background incidences to endogenous formaldehyde, using the measured endogenous N2-hmdG adducts formed by formaldehyde in specific tissues as a biomarker of exposure. Their risk model assumes a linear relation between cancer incidence and N2-hmdG adduct levels over the concentration range of endogenous adducts as well as in the low-exposure range for exogenous adducts.

Risk estimates from this approach are claimed by the authors to produce conservative upper bounds primarily on the grounds that: (a) the method attributes all of the background risks of specific cancers to endogenous formaldehyde (based on N2-hmdG adducts); (b) lower confidence bounds on measured adduct levels are used; and (c) a linear relation is assumed between cancer incidence and N2-hmdG adduct levels over the endogenous range as well as in the low-exposure range of interest for exogenous exposure. Starr and Swenberg (2016) updated their previous estimates using better estimates of tissue specific endogenous and exogenous formaldehyde-DNA adducts in monkeys and an improved estimate of the DNA adduct elimination half-life in rats obtained by Yu et al. (2015a). The revised bottom-up estimates of risk at 1 ppm exposure concentration in (Starr and Swenberg, 2016) were 2.69 × 10^−4^ for NPC and <1.24 × 10^−6^ for leukemia. The authors then compared these values with the risk estimates in EPA’s 2010 draft Toxicological Review that were derived by dose-response modeling of the epidemiological data and linearly extrapolating to lower doses from a POD (a lower bound on the concentration associated with the benchmark response). The authors determined that the 2010 draft EPA upper-bound risk estimates at 1ppm were higher than the adduct-based bottom-up estimates by 40-fold for NPC and over 45,000-fold for leukemia.

There is considerable uncertainty in extrapolating downward from high-dose animal or occupational data, particularly in the case of a dose-response that is highly curvilinear; thus, an approach that allows an upward linear extrapolation in lieu of the traditional downward extrapolation is appealing. The bottom-up approach uses cancer incidence in the general population and is independent of the tumor dose-response data (other than to identify the type of tumors of concern for analysis); therefore, it can potentially provide a perspective on the likely contribution of a specific MOA and on the uncertainty in risk estimates derived from higher dose data where other phenomena such as significant cytotoxicity and impact on DNA repair prior to mutations may be occurring.

EPA evaluated this bottom-up approach and identified scenarios under which this approach would yield an underestimate of the total (endogenous plus exogenous) risk for a specific cancer type, thereby concluding that the method does not necessarily provide an upper bound on the slope of the dose-response at low exogenous exposures. Therefore, the approach in Starr and Swenberg (Starr and Swenberg, 2016) is not carried forward in the candidate unit risks presented in this assessment. Further details are elaborated in Appendix D.2.4. A critique of the approach in (Starr and Swenberg, 2013) along with a response by the authors were published by (Crump et al., 2014) and (Starr and Swenberg, 2014) respectively.

### 5.2.6 Previous IRIS Assessment: Inhalation Unit Risk

In the previous assessment (last updated in 1991), an inhalation unit risk of 1.3 × 10^−5^ per µg/m^3^ was developed based on nasal SCCs in F344 rats from Kerns et al. (1983). The data were modeled from the estimates of the probability of death with tumor and its variance using a linearized multistage procedure.

41 For example, the reported formaldehyde exposure data in epidemiology studies demonstrating associations were generally not amenable to use in quantitative dose-response analysis. In the available animal studies, there were prominent methodological limitations including poor exposure quality; an inability to rule out nonspecific effects due to irritant or odorant responses, or due to conditions unlikely to be relevant to human exposure scenarios; and deficiencies in the reporting of quantitative results important to quantitative analyses (e.g., litter information).

42 Exposure assessment methodology methods was consistent with NIOSH method 3500 (NIOSH, 1994) and were considered to have high accuracy for the 1-hour samples, however there was a concern that the symptom sampling timeframe did not match the exposure ascertainment time-frame.

43 Hanrahan et al. (1984) reported on the “prevalence” of symptoms that had occurred since moving into the home.

44 The dependent variable in both studies was displayed as a predicted percentage prevalence of burning eyes. However, the general epidemiologic method used to model prevalence data is logistic regression, which predicts the log odds of prevalence, which the authors then transformed to prevalence for graphing. In order to describe the underlying functional form of the results displayed, EPA converted the prevalence data back to prevalence odds. Prevalence odds = [Prevalence/(1-Prevalence)].

45 A background of 1% yields a BMC_10_ of 0.174 mg/m^3^; 2% yields 0.182 mg/m^3^; 6% yields 0.213 mg/m^3^; A background of 1% yields a BMCL_10_ of 0.060 mg/m^3^; 2% yields 0.066 mg/m^3^; 6% yields 0.088 mg/m^3^.

46 Model 1, the cumulative odds model, allows the intercept term to vary with severity level, but not the coefficients of dose and time. Model 2, the unrestricted cumulative model, allows any of the parameters to vary with severity level. For details, see the CatReg User Guide (U.S. EPA, 2017).

47 Although a cRfC for hyperplasia was not estimated (see Section 3.2.4 for rationale), a human POD_ADJ_ that can be estimated based on the basal cell hyperplasia end point is roughly two-fold greater than that obtained from the squamous metaplasia data from Woutersen et al. (1989) study. This estimate of hyperplasia provides context to the development of unit risk estimates for nasal cancer (see Section 5.2.1)

48 The data for 27 and 30 mos represent incidence after 3 and 6 mos of nonexposure, respectively, following 24 mos of exposure.

49 Flux (in units of mass/area-time) expresses the net transport of formaldehyde from the inspired air to the air-mucus interface of the nasal lining (prior to disposition within the tissue).

50 As discussed in the Appendix C.1, Schroeter et al. (2014) revised the dosimetry model of (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) used for the flux estimates presented in Table 5-11, to include endogenous formaldehyde production and to explicitly model formaldehyde pharmacokinetics in the respiratory mucosa. EPA estimated the extent to which the results in Table 5-11 change if flux estimates from Schroeter et al. (2014) are used. The average flux over nonsquamous regions of the rat nose is roughly one-third of that in the human based on the dosimetry in Schroeter et al. (2014) in which endogenous formaldehyde is taken into account compared to a ratio of roughly one-half based on the dosimetry in (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001). Thus, the POD is not altered appreciably (changing only by roughly a factor of 1.4) if the revised dosimetry model by Schroeter et al. (2014) is applied.

51 The individual rat data generally allowed for assigning average severity scores for a given nasal level, concentration, and time point. In several cases (as with the 24-month, Level 2), the nasal level was not clear (i.e., the individual rat data could have come from Level 1, 2, or 3).

52 Also, see further discussion below in the analysis of squamous metaplasia in Wistar rats. “PPM equivalence” refers to toxicological equivalence across species when exposures are expressed in “ppm” and are suffered over equal durations expressed in units of the species lifetime. This originates from general allometric principles, wherein tissue exposure is equivalent when scaled by BW^3/4^ while inhalation rates scale as BW^3/4^; these factors cancel each other out when exposure is expressed in ppm.

53 The large population (over 1000 individuals) in Liu et al. (1991) included approximately ⅓ smokers, ½ women, ⅓ individuals with chronic respiratory/allergic conditions, and ⅓ aged 65 and older. The first three groups had a higher symptom prevalence, with women and smokers having a < 1.4-fold increased prevalence of sensory irritation symptoms and those with chronic respiratory/allergy conditions having an approximately 2.5-fold increased prevalence. The authors reported that symptoms did not always increase with age using groupings of 5–19, 20–64, and 65+ years; for nearly half the symptoms, those 20–64 years old had the highest prevalence rates (although it is unclear if this included the sensory irritation symptoms).

54 The Annesi-Maesano study (Annesi-Maesano et al., 2012) used ISAAC-based questions regarding rhinitis and rhinoconjunctivitis symptoms, which was recommended based by the expert panel consulted by EPA regarding study designs used for studies of allergies. For eczema, the Matsunaga study (Matsunaga et al., 2008) used a question relating to medication use for atopic eczema. The panel also noted that retrospective assessment of the prevalence of allergic symptoms using self- or parent-reported questionnaires was an appropriate approach based on the validation work that had been done regarding the accuracy of these measures.

55 The Annesi-Maesano study (Annesi-Maesano et al., 2012) used ISAAC-based questions and the Krzyzanowski study (Krzyzanowski et al., 1990) used ATS-based questions regarding prevalence of current asthma, both of which were recommended based by the expert panel consulted by EPA regarding study designs used for studies of asthma. The panel also noted that retrospective assessment of the prevalence of asthma using self- or parent-reported questionnaires was an appropriate approach based on the validation work that had been done regarding the accuracy of these measures.

56 Studies of other irritants have, on average, identified a factor of ^~^1.8–1.9 for relationships between acute exposure and mortality (i.e., the observed mortality is more attributable to concentration, by 1.8- to 1.9-fold, than duration; see Section 3.2.4). A value for formaldehyde was not identified, nor were values for long-term exposure.

57 It is important to note that while the RfC is based on findings in children, who appear to be susceptible to the respiratory effects of inhaling formaldehyde (Section 4.1), the assessment does not conclude that these respiratory effects do not occur in exposed adults. Section 3.2.2 describes the consistent and strong evidence for declines in pulmonary function in workers with long-term exposure to formaldehyde; however, these long-term occupational studies generally only tested higher (≥ 0.2 mg/m^3^) levels of formaldehyde as compared to the residential studies examining effects in adults or in both adults and children. Section 3.2.3 highlights that there are few studies on the potential effects of formaldehyde on allergic conditions in adults, with concerns noted regarding the methods and imprecise results in those studies that prevent drawing a reliable judgment. However, Section 3.2.3 also shows that studies of workers with long-term exposure to formaldehyde collectively provide strong support for increases in asthma prevalence, but as with pulmonary function these findings are generally at higher formaldehyde levels (> 0.1 mg/m^3^) than the more sensitive residential- and school-based studies in children advanced for the purposes of developing the RfC.

58 Exposure assessments are not conducted or included as part of IRIS toxicological reviews, and authoritative sources on exposure assessment should be consulted. Most recently (as of the time of this assessment), a draft formaldehyde exposure assessment is underway in EPA’s TSCA Office (see https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-evaluation-formaldehyde#re-findings).Although draft, the TSCA risk evaluation provides potentially useful context to the noncancer values in Figure 5-4. Specifically, the draft TSCA evaluation cites studies supporting that, while formaldehyde concentrations in U.S. homes vary, the median is approximately 20 µg/m^3^, with most homes falling below 40 µg/m^3^. Exceptions to this include newly constructed homes, which tend to have higher formaldehyde levels, and trailers and mobile homes, which can have formaldehyde levels an order of magnitude (or more) higher, particularly if they are poorly ventilated, For comparison purposes, the draft TSCA risk evaluation uses recent (2023) ambient monitoring data to estimate U.S. formaldehyde concentrations in outdoor air to have a median of 1.88 µg/m^3^ (95^th^ percentile range: 0.382 to 6.2 µg/m^3^). It is important to emphasize that estimates can vary substantially, and that these estimates (provided for contextual purposes) are not final.

59 EPA’s approach to deriving an IUR for myeloid leukemia is described in Appendix D.2.3. This provides some context regarding the potential magnitude of the total cancer risk had a more certain analysis of myeloid cancer risk been achievable, with the estimate interpreted by EPA as the best that could be currently derived suggesting the combined risk of NPC and myeloid leukemia together is 4-fold higher than the risk for NPC alone. Although the magnitude is uncertain, the IUR based on NPC alone is certainly an underestimate.

60 This program is an adaptation of the approach that was previously used in BEIR IV, “Health Risks of Radon and Other Internally Deposited Alpha Emitters.” National Academy Press, Washington, DC, 1988, pp. 131–134. A spreadsheet illustrating the life table used for the extra risk calculation for the derivation of the LEC_0005_ for NPC incidence is presented in Appendix D.2.1.

61 Typically, 5-year ranges are used as the basis for population cause-specific disease and mortality rates; a larger range is used here to get better stability in the rates because NPC is a rare cancer.

62 Centers for Disease Control and Prevention, National Center for Health Statistics. Underlying Cause of Death on CDC WONDER Online Database. Accessed at http://wonder.cdc.gov/ucd-icd10.html on September 19, 2013.

63 Eleven NPCs were reported on death certificates and included in NCI’s SMR analyses, but one of these cases was apparently misclassified on the death certificate, so only 10 cases were used to estimate the RRs in the internal comparison analyses (Beane Freeman et al., 2013).

64 The crude NPC (ICD-10 C11.0-C11.9) incidence rate from 2000−2010 SEER-18 data was obtained from the SEER public-use database (www.seer.cancer.gov) using NCI’s SEER*Stat software (www.seer.cancer.gov/seerstat). This value is similar to a published NPC incidence rate for the United States of 0.7/100,000 person-years (Lee and Ko, 2005). The age-adjusted NPC incidence rate from SEER was also 0.75/100,000.

65 With the application of age-dependent adjustment factors (see Section 5.2.4), the lifetime unit risk estimate for NPC would increase by a factor of 1.42, and the crude upper-bound estimates of the incident cases per year attributable to formaldehyde exposure would similarly increase by a factor of 1.42. The resulting adjusted upper-bound estimates of 260 and 1,030 for 5- and 20-ppb exposure levels, respectively, are still well below the estimated total number of 2,300 incident cases per year in the United States.

66 0.33 at 0.1 ppm, 0.32 at 1 ppm.

67 This is an approximate estimate for resting inspiration. The various components of the BBDR modeling were not recalibrated or rerun in light of the revised flux estimates for both species.

68 They also modeled the data using functions that were constrained to pass through the origin but do not report BMCL values.

69 As the regions analyzed varied across studies, comparisons in Appendix C.7 and in Figure 5-6 compare proliferation observed in locations as near to the anterior lateral meatus as possible, as this region was most commonly reported across studies and is a region at which tumors have commonly been observed (see Section 3.2.5, URT cancer in experimental animals).

70 The comparison with mortality estimates appeared appropriate since the tumors were modeled as rapidly fatal in (Conolly et al., 2003, 2004).

71 In this assessment, adult-exposure-only unit risk estimates refer to estimates derived from the life-table analysis assuming exposure only for ages ≥16 years. The adult-exposure-only unit risk estimates are merely intermediate values in the calculation of adult-based unit risk estimates and should not be used in any risk calculations. Adult-based unit risk estimates refer to estimates derived after rescaling the adult-exposure-only unit risk estimates to a (70-year) lifetime, as described later. The adult-based unit risk estimates are intended to be used in ADAF calculations (U.S. EPA, 2005b) for the computation of extra risk estimates for specific exposure scenarios. Note that the unit risk estimates in this section, which are derived under an assumption of increased early-life susceptibility, supersede those that were derived in Section 5.2.1 under the assumption that RR is independent of age.

72 Another study, by (Marsh et al., 1996; Marsh et al., 2002; Marsh et al., 2007a), also derived exposure estimates for the individual workers; however, it examined one of the 10 plants included in the NCI study, and thus, is not an independent study.

73 EPA relied on the results of the NCI exposure-response analyses and did not investigate other possible exposure-response models beyond those conducted by NCI.

74 In the previous follow-up of the NCI cohort by Hauptmann et al. (2004), 10 NPCs were reported on death certificates and included in NCI’s SMR analyses, but one of these cases was apparently misclassified on the death certificate, so only nine cases were used to estimate the RRs in the internal comparison analyses; the misclassified case was not from the Wallingford plant (Beane Freeman et al., 2013).