# 4 SUMMARY OF HAZARD IDENTIFICATION CONCLUSIONS

This section provides summaries of the available evidence on susceptible populations and life stages and on populations that may have heightened formaldehyde exposures compared to the general population (Section 4.1), the weight of evidence for effects other than cancer (Section 4.2), and the weight of evidence for carcinogenicity (Section 4.3).

## 4.1 SUSCEPTIBLE POPULATIONS AND LIFESTAGES

Susceptible populations and lifestages refer to groups of people who may be at increased risk for adverse health consequences following chemical exposures due to factors such as age, genetics, health status and disease, sex, lifestyle, and other coexposures. This discussion of susceptibility focuses on factors for which there are available formaldehyde exposure-specific data and on factors hypothesized to be important to formaldehyde. Vulnerable populations, defined as groups that may be at an increased risk for adverse health consequences due to heightened formaldehyde exposures, are also discussed.

### 4.1.1 Lifestage

Embryos, fetuses, infants, children, and the elderly may have differing levels of maturity and functioning of cellular and organ systems, and metabolizing enzymes, as well as unique activity patterns that may influence the toxicodynamics of chemicals in the body. Embryonic, fetal, neonatal, and juvenile periods, as well as reproductive lifestages in both men and women, are often periods of increased susceptibility to negative health consequences following chemical exposures.

#### Developmental and reproductive effects

The Developmental and Reproductive Toxicity (Section 3.3.2) provides a detailed analysis of human and animal studies evaluating susceptibility to formaldehyde toxicity while in utero and during infancy, childhood, and reproductive lifestages. Overall, it was judged that the available evidence indicates that formaldehyde inhalation exposure likely causes developmental or reproductive toxicity in humans. This hazard conclusion was primarily based on moderate evidence from epidemiological studies of women that reported decreased fecundity and increased spontaneous abortion risk at occupational exposure levels as high as 1.2 mg/m^3^ (Taskinen et al., 1999; John et al., 1994) as well as effects on fetal growth among three pregnancy cohorts observed at indoor formaldehyde concentrations >0.04 mg/m^3^, and possibly lower (Franklin et al., 2019; Chang et al., 2017; Amiri and Turner-Henson, 2017).

Further research is needed to determine if the increased spontaneous abortion risk and decreased fecundity in occupationally exposed women is due to toxicity to the reproductive system or to the developing fetus. Additionally, there is a need for more targeted evaluation of the female reproductive system following inhalation exposure to formaldehyde, including an assessment of female reproductive function, such as would be assessed in a two-generation reproductive study in animals. Further assessment of both female reproductive toxicity and developmental toxicity would benefit from the use of paraformaldehyde instead of formalin to avoid possible confounding exposures to methanol.

Several animal studies raise the possibility that formaldehyde exposure might also cause toxicity to the developing nervous system; however, due to methodological limitations, these data were considered inconclusive (i.e., evidence suggests). Three publications from one laboratory (Songur et al., 2003; Sarsilmaz et al., 2007; Aslan et al., 2006) reported changes in brain structure and neuron numbers following developmental exposure to formaldehyde. However, two of these studies were evaluations of the same animals, and all three studies possessed notable methodological limitations and tested formaldehyde levels >7 mg/m^3^, which introduces uncertainties (e.g., differences in toxicokinetics; irritant effects not experienced by humans) in relating these data to the potential for effects in exposed humans. The changes in brain structure and neuron number were not tested using similarly sensitive protocols in adult animals, although less rigorous evaluations failed to observe effects, highlighting additional data gaps. Only low confidence studies evaluated other potential neurodevelopmental effects (i.e., the evidence is indeterminate).

#### Children

Lungs in children are underdeveloped at birth and are not fully functional until about 6 to 8 years of age (Bateson and Schwartz, 2008); therefore, children may be more susceptible to the respiratory effects of formaldehyde, compared to adults. In addition, formaldehyde exposure has been associated with airway inflammation (see Section 3.2.3), which could have a greater impact on children’s airways because they are narrower than adult airways (OEHHA, 2003). This is supported by studies of other chemicals suggesting that human sensitivity to sensory irritation may also be dependent on age (Shusterman, 2007; Hummel et al., 2003). The distribution of inhaled formaldehyde may be different for children compared with adults as well. For example, population variability in distribution is influenced by differences in physical characteristics of the URT, breathing patterns (e.g., oral versus nasal), and ventilation rate. However, studies suggest that extrathoracic absorption of highly reactive and soluble gases, such as formaldehyde, is similar between children and adults (Ginsberg et al., 2005; Ginsberg et al., 2010), as is overall uptake efficiency, average flux, and maximum flux levels over the entire nasal lining (Garcia et al., 2009). Garcia et al. (2009) did find that local flux between the seven individuals (five adults and two children) in his study varied by a factor of three to five, which is important as formaldehyde toxicity is likely to be mediated by its point-of-contact effects along the URT. Because this study only evaluated seven individuals who had normally shaped nasal cavities, it may not be generalizable to the entire population, including susceptible individuals. Notably, formaldehyde distribution to more distal parts of the airways could be substantial under conditions of higher activity and oral breathing, both of which occur with children.^39^

The expression of formaldehyde metabolizing enzymes may also be different in infants and children. The metabolism of formaldehyde is described in more detail in Appendix C.1. Briefly, expression of glutathione-dependent formaldehyde dehydrogenase, also called alcohol dehydrogenase class III, ADH3, or ADH5, the primary enzyme in formaldehyde metabolism, is developmentally regulated and thus may alter the toxicokinetics of formaldehyde in early life (Reviewed in (Thompson et al., 2009; Hines and McCarver, 2002)). ADH3 is critical to the detoxification of formaldehyde, as it is involved in the pathway leading to formaldehyde’s conversion to formate, a metabolite that is excreted from the body. Therefore, if the concentration or activity of ADH3 is reduced, more formaldehyde is likely to remain in the body to react with cellular macromolecules. ADH3 mRNA expression levels are significantly lower in premature neonates and infants up to 5 months old compared with adults. Benedetti et al. (2007) reported that ADH activity reached adult levels by 2.5 to 5 years of age. Thus, neonates and very young children, in particular, may have a decreased ability to metabolize formaldehyde, increasing their susceptibility to formaldehyde toxicity; however, enzyme activity levels for ADH3 specifically, and the potential for alternate metabolic pathways in children, are not known.

Some epidemiological studies have found that children have an increased sensitivity to formaldehyde exposure-induced respiratory effects. One study reported a relationship between increased residential formaldehyde exposure and decreased PEFR (both bedtime and morning) among children exposed to levels averaging 0.032 mg/m^3^ (Krzyzanowski et al., 1990). In adults, an association of smaller magnitude was observed, but only among smokers. Krzyzanowski et al. (1990) also reported an increase in the prevalence of physician-diagnosed asthma in children, but not in adults, who lived in homes with formaldehyde levels that were higher than 60 ppb (0.074 mg/m^3^). Similarly, a study by Zhai et al. (2013) reported a higher prevalence of current asthma in children compared with adults at the same exposure levels in their homes. Although prevalence of current asthma (i.e., symptoms or use of medications in the past 12 months) does not appear to be increased among adults or children below exposure levels of approximately 0.05 mg/m^3^, studies of the exacerbation of asthma symptoms (asthma control) among children suggest their greater susceptibility at lower average formaldehyde concentrations (e.g., 0.04 mg/m^3^; (Venn et al., 2003; Dannemiller et al., 2013). Children younger than five years of age also may experience symptoms consistent with lower respiratory infections in association with residential formaldehyde levels lower than those at which older individuals experience these symptoms (Rumchev et al., 2002; Roda et al., 2011).

Children are also likely to be more susceptible than adults to the mutagenic effects of formaldehyde. EPA has concluded that early-life exposure to chemicals that are carcinogenic through a mutagenic MOA might present a higher risk of cancer than exposure during adulthood (U.S. EPA, 2005b). Because formaldehyde-induced carcinogenicity of the URT is attributable, at least in part, to a mutagenic MOA (see Section 3.2.5), it is expected that children are at heightened risk of URT cancers following formaldehyde exposure. In contrast, because it is unknown whether myeloid leukemia resulting from formaldehyde exposure involves a mutagenic MOA, no assumption about increased early-life susceptibility is made for this type of cancer.

#### Pregnant women

Because pregnant women have increased sensitivity to the development and exacerbation of atopic eczema (Weatherhead et al., 2007; Kar et al., 2012; Cho et al., 2010), it is likely that they also have heightened susceptibility to this form of dermatitis following exposure to formaldehyde. To date, however, no studies are available that specifically evaluate the prevalence of atopic eczema in pregnant women compared to other populations following exposure to formaldehyde. In one study, Matsunaga et al. (2008) found a two-fold higher risk for atopic eczema in pregnant women with formaldehyde exposures of greater than approximately 0.05 mg/m^3^ measured in their homes.

#### Later lifestages

In general, older adults may have greater susceptibility than younger adults to chemical exposures due to slower metabolisms and an increased incidence of altered health status (Ginsberg et al., 2005; Benedetti et al., 2007). One study (Bentayeb et al., 2015) indicated possible differential effects of formaldehyde exposure for elderly adults (>65 years old) compared with other age groups. Bentayeb et al. (2015) observed an elevated risk of decreased pulmonary function in nursing home residents at lower formaldehyde exposure levels than have been seen to cause effects in younger adults.

### 4.1.2 Health Status and Disease

Preexisting health conditions and diseases may predispose individuals to toxic effects following exposure to formaldehyde. Some epidemiological studies have suggested that asthmatics are more susceptible than nonasthmatics to declines in respiratory function following formaldehyde exposure. Krzyzanowski et al. (1990) found that asthmatic children showed a steeper decline in morning peak expiratory flow rate (PEFR) compared with nonasthmatic children at formaldehyde concentrations below 0.05 mg/m^3^. Similarly, a study by Kriebel et al. (1993) reported a greater decrease in peak expiratory flow (PEF) in asthmatic, compared with nonasthmatic, medical students after formaldehyde exposures in an anatomy lab. However, this study (Kriebel et al., 1993) had a small sample size and the effect was not statistically significant.

Studies evaluating effect modification by existing allergies are inconsistent. Acute and short-term studies in two animal species demonstrate that formaldehyde increases responsiveness to allergens and bronchoconstrictors, particularly with prior sensitization, indicating that allergy status may modify an individual’s sensitivity to bronchial hyperreactivity and other asthma symptoms due to formaldehyde exposure (Swiecichowski et al., 1993; Riedel et al., 1996; Leikauf, 1992; Larsen et al., 2013). However, studies of associations with eczema, prevalence of asthma or asthma control were inconsistent, reporting either an increased or decreased prevalence among groups with a positive atopy status in adults or children (Venn et al., 2003; Smedje and Norback, 2001; Matsunaga et al., 2008; Annesi-Maesano et al., 2012). The evidence, therefore, is inconclusive and additional research is needed to address the question of potential effect modification by atopy status. Separately, the swelling of the mucus membrane, which has been observed in humans exposed to <1 mg/m^3^ formaldehyde (see Section 3.2.4), is expected to be highly influenced by the underlying respiratory status of the exposed individuals, such as allergy status or previous or current respiratory infections. Supporting this assumption, nasal lesions have been found to be more severe in formaldehyde-exposed rodents with prior nasal damage (Woutersen et al., 1989; Appelman et al., 1988), and similar observations have been made in exposed humans (Falk et al., 1994). Therefore, individuals with prior nasal damage might also have heightened subsceptibililty to the development of nasal cancer following formaldehyde exposure.

As discussed in Section 3.1, nasal anatomy and soluble factors in the URT play a major role in the uptake of a highly reactive gas like formaldehyde. There are considerable interindividual variations in nasal anatomy (ICRP, 1994). For example, the nasal volumes of 10 adult nonsmoking subjects between 18 and 50 years of age in a study in the United States varied between 15 and 60 mL (Santiago et al., 2001), and disease states can result in further variation (Singh et al., 1998). Therefore, population variability in the distribution of inhaled formaldehyde, and in the susceptibility to its health effects, could potentially be large.

To date, many other factors related to health, such as obesity, have not been investigated to determine if they affect susceptibility to formaldehyde-related adverse effects.

### 4.1.3 Sex

Males and females can differ greatly in body composition, organ function, and many other physiological parameters that may influence the toxicokinetics of chemicals and their metabolites in the body (Gochfeld, 2007; Gandhi et al., 2004). The human epidemiology data set does not support many specific sex susceptibilities for noncancer effects due to formaldehyde exposure. However, in general, data suggest that nonpregnant women, on a per kilogram body weight basis, may have slightly lower air intake than men, which would suggest that women may be less susceptible than men to inhaled pollutants like formaldehyde, but this has not been investigated to date.

Similar to age and allergy and respiratory infection status, studies of related chemicals suggest that human sensitivity to sensory irritation may also be dependent on sex (Shusterman, 2007; Hummel et al., 2003). It is likely that women may be more sensitive than men to the eye and URT irritant properties of formaldehyde. For example, a higher prevalence of burning or tearing eyes was observed among women compared to men in a study of residential exposure (Liu et al., 1991).

In contrast, several animal studies suggest that males may be more susceptible than females to histopathological lesions of the URT, although most studies only examined male animals. For example, one study in rats reported that males generally had more severe damage, including metaplasia, to the nasal respiratory and olfactory epithelium and larynx following formaldehyde exposure (Woutersen et al., 1987). Supportive findings of increased incidence or severity of lesions in males as compared to females was also reported in a second study of rats (Zwart et al., 1988), and in mouse studies of (Maronpot et al., 1986; Kerns et al., 1983). Male rats have a higher metabolic rate and oxygen demand than do female rats; therefore, these findings might reflect a greater inhaled dose of formaldehyde in males compared to females at similar exposure concentrations.

It is also concluded that the evidence indicates formaldehyde exposure likely causes sex-specific health effects related to reproduction, given sufficient exposure conditions. Specifically, a coherent spectrum of male reproductive effects was observed in experimental animal studies following exposure to high levels of formaldehyde, with supporting evidence in a well-conducted human study. In addition, epidemiological studies identified decreased fecundity and increased spontaneous abortion risk in women occupationally exposed to formaldehyde. This evidence could reflect developmental effects, or changes in the female reproductive system.

### 4.1.4 Race

Race may be a modifying factor of formaldehyde toxicity, for example, if specific polymorphisms in metabolizing enzymes affecting chemical toxicokinetics are more prevalent in specific races. Additionally, lifestyle factors that modify toxicity may be more or less prevalent in specific races. The only study to evaluate the potential role of race in carcinogenicity (Hayes et al., 1990) found significantly increased death rates from nasopharyngeal cancer and multiple myeloma in nonwhite embalmers and funeral directors; whereas no changes in death rates from nasopharyngeal cancer or in cases of multiple myeloma were found in white embalmers and funeral directors. Very few other studies have explored the role of race in formaldehyde susceptibility, preventing the interpretation and generalizability of this observation.

A more detailed description of the role of polymorphisms in susceptibility is provided below. Additional research is needed to confirm the findings in Hayes et al. (1990).

### 4.1.5 Genetic Polymorphisms

Genetic polymorphisms may affect the expression level of genes and resulting activity of important metabolizing enzymes, and this may lead to differential toxicity following chemical exposures. As discussed in Appendix C.1, the primary metabolizing enzyme of formaldehyde is ADH3 (referred to as ADH5 in recent papers). A secondary pathway involves mitochondrial aldehyde dehydrogenase 2 (ALDH2). Both ADH3 and ALDH2 are important in the detoxification of formaldehyde, converting it to formate, which is readily excreted from the body. ADH3 is also known to catalyze the NADP-dependent reduction of the endogenous nitrosylating agent S-nitrosoglutathione (GSNO) and, in this capacity, is referred to as S-nitrosoglutathione reductase (GSNOR) (Jensen et al., 1998). GSNOR participates in the oxidation of retinol and long-chain primary alcohols. It also contributes to nitric oxide (NO) signaling through its role in metabolizing GSNO an endogenous bronchodilator and reservoir of NO (Staab et al., 2008; Jensen et al., 1998; Hess et al., 2005), indicating ADH3’s involvement in bronchial tone allergen-induced hyperresponsiveness (Que et al., 2005; Hess et al., 2005; Gerard, 2005).

Wu et al. (2007) found that carrying one or two copies of the minor allele rs1154404 for a single nucleotide polymorphism (SNP) of ADH3 resulted in a decreased risk of asthma in Mexican children. For a different SNP (rs28730619), homozygotes for the minor allele had an increased risk of asthma. Although only speculative as their functional characteristics are unknown, these SNPs may affect the response of individuals to formaldehyde exposure by altering their metabolism. One study (Hedberg et al., 2001) identified four polymorphisms in the human ADH3 gene promoter that resulted in reduced transcriptional activity. Because this would likely result in reduced levels of the ADH3 protein, individuals with this polymorphism may be at greater risk for formaldehyde toxicity compared with people with the wild-type gene. This is supported by a study in which deletion of the ADH3 gene increased the sensitivity of mice to formaldehyde toxicity (Deltour et al., 1999).

Some studies have also suggested that CNS toxicity can result from reduced activity of the metabolizing enzymes responsible for clearing formaldehyde from relevant tissues (e.g., downregulated ALDH2 in Tan et al. (2018)). Therefore, it is plausible that individuals with polymorphisms in ALDH2 or in other genes encoding detoxifying enzymes may be more susceptible to CNS toxicity caused by formaldehyde exposure compared to those with wild type alleles. This highlights another area of interest for future studies on potential susceptibility to inhaled formaldehyde exposure.

A few studies of genotoxicity among formaldehyde-exposed groups evaluated differences in response based on polymorphisms in genes coding for proteins involved in the metabolism of xenobiotics, including CYP2E1, glutathione-S-transferases (GSTs), and ADH3. The X-ray repair cross-complementing gene 3 (XRCC3), which codes for a protein involved in DNA repair and chromosome stabilization, also was evaluated (Santovito et al., 2011; Ladeira et al., 2013; Jiang et al., 2010; Costa et al., 2015). The results of these studies were inconsistent and no conclusions regarding the impact of these genetic polymorphisms on susceptibility can be drawn. (e.g., (Shen et al., 2016; Rager et al., 2014))

Studies of mice with knocked out Aldh2 and Aldh5, which encode for enzymes that remove endogenous formaldehyde, have suggested that polymorphisms in Aldh2 and Aldh5, may increase susceptibility to genotoxicity. These knockouts resulted in severely disrupted hematopoiesis and leukemia, including mutated and abnormal HSPCs, which is presumably linked to increased accumulation of endogenous formaldehyde (Pontel et al., 2015; Dingler et al., 2020; Burgos-Barragan et al., 2017b). Likewise, direct treatment of Aldh5-/- bone marrow cells with formaldehdye caused genotoxicity and reduced HSPC formation, effects which are further exacerbated by loss of Fancd2 (this latter deficiency is associated with increased sensitivity to DNA damage) (García-Calderón et al., 2018; Burgos-Barragan et al., 2017b). As reviewed and tested by Dingler et al. (2020), genetic deficiencies in these Aldh family genes have been linked to bone marrow failure and related diseases in humans, including in children. Reduced ALDH2 or ALDH5 activity resulting in increased endogenous formaldehyde in mice and humans might also contribute to postnatal lethality, stunted growth, cognitive effects (see Section 1.3.1) and various cancers arising from DNA damage or deficient repair (Nakamura et al., 2020; Dingler et al., 2020). While formaldehyde inhalation does not seem to cause appreciable changes in formaldehyde levels in nonrespiratory regions (see Appendix C.1), HSPCs expressing these enzymes are known to exist in many tissues. However, no studies in any species have specifically examined these possible linkages in relation to inhaled formaldehyde. Therefore, while genetic differences may alter susceptibility to the cytogenetic effects of formaldehyde, more definitive research is needed. A few in vitro studies have suggested that epigenetic changes or loss of function of important genes might increase susceptibility to formaldehyde toxicity (e.g., (Shen et al., 2016; Rager et al., 2014)). However, additional studies are needed to clarify these preliminary observations.

### 4.1.6 Lifestyle Factors

Lifestyle factors may increase or decrease exposure to formaldehyde and may also affect the resulting health effects following formaldehyde exposure. These lifestyle factors may vary by race, ethnicity, socio-economic status, or geographic location. To date, specific studies do not exist to address the role of lifestyle factors on formaldehyde toxicity.

#### Nutritional status

Because formaldehyde appears to cause inflammation, particularly in the airways, it is plausible that a diet rich in antioxidants would protect against inflammation and one that lacks sufficient antioxidants would result in greater inflammation. Additional research is needed to specifically evaluate possible modification of formaldehyde toxicity by nutritional status.

#### Smoking

Smoking is considered a lifestyle factor, but it also introduces coexposures to the many chemicals in cigarette smoke, including additional formaldehyde. Thus, it is difficult to disentangle potential indirect contributions of smoking to the health effects of formaldehyde exposure from the possible direct effects of the formaldehyde in tobacco smoke (see additional discussion below under “coexposures”).

#### Exercise

The possibility that more extensive distribution of formaldehyde (e.g., to the LRT) may occur when people are breathing through the mouth during exercise has not been investigated. However, some controlled human exposure studies observed pulmonary function deficits when a longer exercise component (15 minutes) was included that were not observed by other studies with shorter periods or no exercise (Green et al., 1987; Green et al., 1989), and another study observed an increase in bronchial hyperresponsiveness with an exposure protocol using nose clips necessitating mouth-only breathing (Casset et al., 2006). Clearly, further research is warranted to understand the role of exercise in formaldehyde susceptibility.

### 4.1.7 Coexposures

Coexposures to other pollutants, such as those that produce similar metabolites and health effects to formaldehyde and those that are mutagens, may exacerbate the effects of formaldehyde exposure. In addition, constituents in the diet, such as methanol and caffeine, contribute to the generation of endogenous formaldehyde in nonrespiratory tissues (Summers et al., 2012; Riess et al., 2010; Hohnloser et al., 1980), which are promptly detoxified (Burgos-Barragan et al., 2017a). Yet, it is not expected that variation in endogenous formaldehyde levels at sites distal to the URT would affect relative sensitivity to the effects of inhaled formaldehyde. These findings are inconclusive, however, so additional research is needed to investigate the role of these coexposures.

As described in Section 3.2.3, tobacco smoke may increase the incidence of hypersensitivity responses in formaldehyde-exposed individuals. Effect modification by environmental tobacco smoke (i.e., stronger associations, or associations seen at lower formaldehyde exposures, with this coexposure) were reported in two studies that examined asthma prevalence stratified by environmental tobacco smoke exposure among children and adults (nonsmokers) (Palczynski et al., 1999; Krzyzanowski et al., 1990). Additional studies are needed to establish if this interaction is seen only in children, in adults and children, or in neither group. One residential study by Krzyzanowski et al. (1990) indicated that smokers experienced a greater decline in morning PEFR compared to nonsmokers at formaldehyde concentrations above 0.050 mg/m^3^. Smokers were not more responsive to formaldehyde exposures in most occupational studies that stratified by smoking behavior. Nonsmokers experienced 2- to 3.5-fold larger annual decreases in FEV_1_, FEV_1_/FVC, and FEF_25-75_ over 5 years (Alexandersson and Hedenstierna, 1989), as well as larger declines during a work shift (Alexandersson et al., 1982; Alexandersson and Hedenstierna, 1989). In contrast, current smokers had an approximately two-fold larger OR for airway obstruction, defined as an FEV_1_/FVC <75%, compared with nonsmokers (Herbert et al., 1994). The magnitude of the difference associated with formaldehyde exposure may have reflected the existing difference in baseline pulmonary function values between smokers and nonsmokers.

Although not a chemical coexposure, humidity also appears to modify the effects of formaldehyde exposure. For example, formaldehyde exposure-induced bronchoconstriction in mice housed only in humid, but not dry, environments indicating that the bronchoconstrictive effects of formaldehyde may be impacted by humidity (Larsen et al., 2013). The effects of formaldehyde on mucus flow patterns also appear to vary based on humidity.

In addition, it is possible that exposure to nonchemical stressors, such as poverty, violence, and other social factors, might make some populations more susceptible to formaldehyde-related health effects. However, at this time, studies evaluating the contribution of nonchemical stressors to formaldehyde susceptibility have not been published.

Additional research is needed to investigate whether coexposures to pollutants other than tobacco smoke and to nonchemical stressors confer additional susceptibility to formaldehyde toxicity.

### 4.1.8 Summary of Susceptible Populations and Lifestages

Epidemiological and toxicological studies identify reproductive or developmental toxicity as a human health hazard of formaldehyde exposure. At this time, it is not clear whether increased time-to-pregnancy (TTP) and spontaneous abortion rates seen in occupationally exposed women are due to reproductive system toxicity or to toxicity to the developing fetus.

Children also appear to be a susceptible population. Studies have indicated that they have an increased sensitivity to respiratory and immunological effects following formaldehyde exposure. In addition, younger age is likely to be associated with a higher risk of mutagenic effects and, therefore, to a higher risk of URT cancers. As age may be a modifying factor of the sensory irritant properties of formaldehyde, both children and the elderly may be at an either increased or decreased risk for sensory irritation.

Health status and disease are likely to be modifying factors of formaldehyde toxicity as well. Studies suggest that asthmatics are more susceptible than nonasthmatics to declines in respiratory function following formaldehyde exposure. Whether atopy and allergies can also influence the health effects of formaldehyde exposure remains to be determined; additional studies are needed to confirm this relationship. Individuals with prior nasal damage might also have heightened susceptibility to the development of nasal cancer following formaldehyde exposure.

Study findings on the role of genetic susceptibility in formaldehyde toxicity are inconclusive. Therefore, gene-environment interaction studies are needed to investigate the effects of polymorphisms in genes that encode formaldehyde metabolizing enzymes, as well as receptors (e.g., TRPA1) or other proteins that appear to be key components of the MOA for certain human health effects of formaldehyde exposure.

Coexposures appear to increase susceptibility to health effects following formaldehyde exposure as well. There is some evidence that cigarette smoking increases sensitivity to formaldehyde toxicity; however, it is not clear if this increased sensitivity is due to the additional formaldehyde to which smokers are exposed, to exposures to other chemicals that are present in cigarette smoke, or to compromised respiratory systems.

Although other factors are hypothesized to confer increased susceptibility to formaldehyde toxicity, the available data are limited. Overall, the most extensive research on the health effects of inhaled formaldehyde and susceptible groups indicates a greater susceptibility among children to respiratory disease, manifested as reduced pulmonary function, increased prevalence of current asthma, and greater asthma severity (reduced asthma control). More research is needed to investigate the role of sex, race, nutrition, exercise, and other coexposures that may modulate susceptibility to formaldehyde toxicity. In addition, these susceptibility factors might interact with one another. For example, lifestage, pre-existing health conditions, genetic polymorphisms and co-exposures to both chemical and nonchemical stressors could all contribute to heightened susceptibility to formaldehyde toxicity for some individuals.

### 4.1.9 Summary of Vulnerable Population

Groups that may receive disproportionally high levels of exposure to formaldehyde, and therefore might experience more frequent or severe formaldehyde-related health consequences, include people in occupations with workplace exposures. Some industries with the greatest potential for exposure include health services, business services, printing and publishing, chemical manufacturing, garment production, beauty salons, and furniture manufacturing (IARC, 1995). People who spend a significant amount of time in mobile homes and trailers, either as primary residences, classrooms, job sites or for other reasons, might also be vulnerable because these structures can have high formaldehyde levels (Murphy et al., 2013). Lastly, in addition to the potential of cigarette smoking to increase susceptibility to formaldehyde, it also can increase exposure to it (Fishbein, 1992). It should be noted that individuals who are both susceptible and highly exposed to formaldehyde are at the highest risk of suffering from formaldehyde-related health effects.

## 4.2 SUMMARY OF CONCLUSIONS FOR NONCANCER EFFECTS

Overall, the evidence demonstrates that inhalation of formaldehyde causes sensory irritation and respiratory pathology in humans, given sufficient exposure conditions, based on studies of the general population with residential exposure, controlled human exposure studies, and occupational studies. The evidence indicates that inhalation of formaldehyde likely causes decrements in pulmonary function, and an increased frequency of current asthma symptoms and allergic responses, given sufficient exposure conditions, based on studies of adults and children exposed in their homes or at school. In addition, the evidence indicates that inhalation of formaldehyde likely causes female reproductive or developmental toxicity, and reproductive toxicity in males, given sufficient exposure conditions, based on studies involving residential and occupational exposure and toxicological studies. Lastly, while a number of studies reporting evidence of potential neurotoxic effects were available, including developmental neurotoxicity, multiple manifestations of behavioral toxicity, and an increased incidence of, or mortality from, the motor neuron disease, amyotrophic lateral sclerosis (ALS), due to limitations identified in the database (e.g., poor methodology; lack of consistency), the evidence integration analyses for these outcomes determined that the evidence suggests, but is not sufficient to infer, a human health hazard(s). The data on potential nervous system effects were considered insufficient for developing quantitative estimates of risk. Context on these decisions is provided below:

- Sensory Irritation:
  ○ The evidence demonstrates that inhalation of formaldehyde causes sensory irritation in humans, given sufficient exposure conditions, based on robust human evidence from controlled human exposure studies testing responses to concentrations 0.1 mg/m^3^ and above and observational epidemiology studies of residential populations with mean formaldehyde concentrations >0.05 mg/m^3^ (range of 0.01 to approximately 1.0 mg/m^3^), robust evidence for an effect in animals (this phenomenon is well described and accepted across a range of experimental species), as well as an established MOA based on mechanistic evidence in animals (the identified MOA is interpreted to be operant in humans). The irritant response occurs within minutes to hours depending on concentration, and severity is concentration dependent. Potentially large variations in sensitivity are expected, depending primarily on differences in nasal health (including allergy or inflammatory status) and physiology.
- Pulmonary Function:
  ○ The evidence indicates that long-term (chronic) inhalation of formaldehyde likely causes decrements in pulmonary function, given sufficient exposure conditions, based on moderate human evidence primarily from observational epidemiology studies among occupational cohorts with long-term exposure to >0.2 mg/m^3^ and a study of children and adults with residential exposure (mean, 0.03 mg/m^3^, maximum 0.17 mg/m^3^), as well as slight evidence for an effect in animals involving inflammatory airway changes in mechanistic studies (it is expected that related mechanistic changes can occur in exposed humans, and some indirect confirmatory evidence from exposed humans exists).
- Respiratory Tract Pathology:
  ○ The evidence demonstrates that inhalation of formaldehyde causes increased respiratory tract pathology in humans, including hyperplasia and squamous metaplasia, given sufficient exposure conditions, based on robust evidence from animal studies involving multiple species with increases in severity and frequency of lesions with increasing concentration or longer exposure duration. The primary support for this conclusion is based on rat bioassays of chronic exposure which consistently observed squamous metaplasia at formaldehyde exposure levels ≥2.5 mg/m^3^. There is moderate human evidence from occupational epidemiology studies supported by more limited findings in mechanistic studies of exposed humans, and strong support for a plausible MOA based largely on mechanistic evidence in animals (supported by coherent findings in human studies). Variation in sensitivity may depend on differences in URT immunity and nasal structure or past injury, but few studies exist that specifically evaluate these possibilities.
- Immune-mediated Conditions, including Allergies and Asthma:
  ○ The evidence indicates that inhalation of formaldehyde likely causes increases in the prevalence of allergic conditions in humans, given sufficient exposure conditions, based on moderate evidence of an enhanced immune hypersensitivity response to allergens (i.e., allergic rhinitis or rhinoconjunctivitis; eczema) in general population studies of adults and children at average exposures between 0.04 and <0.1 mg/m^3^ formaldehyde, and slight evidence of effects relevant to immune-mediated respiratory conditions in animals from mechanistic studies of airway hyperresponsiveness and some more limited data relevant to systemic inflammatory changes in both human and animal mechanistic studies; however, the proposed, incomplete MOA(s) are not established and have not been experimentally verified.
  ○ The evidence indicates that inhalation of formaldehyde also likely causes increases in the prevalence of asthma symptoms in humans, given sufficient exposure conditions, based on moderate evidence of an increased risk of prevalent current asthma in occupational settings (>0.1 mg/m^3^) and population studies in adults and children, or poor asthma control in children at exposures above 0.05 mg/m^3^ formaldehyde and slight evidence for effects in animals from mechanistic studies; however, an MOA explaining this association is not available. Specifically, regarding the animal evidence, although several events typically associated with asthma are not well supported by the available data, the animal mechanistic data support that formaldehyde inhalation induces bronchoconstriction with and without allergen sensitization and stimulates a number of immunological and neurological processes that would be expected to augment or drive asthmatic responses. Variation in sensitivity is anticipated depending on respiratory health, age, and exposure to tobacco smoke.
- Developmental and Reproductive Toxicity:
  ○ The evidence indicates that inhalation of formaldehyde likely causes developmental or female reproductive toxicity in humans given sufficient exposure conditions, based on moderate evidence in observational studies finding effects on fetal growth among pregnancy cohorts observed at indoor formaldehyde concentrations >0.04 mg/m^3^, and possibly lower, as well as increases in TTP and spontaneous abortion risk among occupationally exposed women (average formaldehyde concentrations >0.1 mg/m^3^); the evidence in animals is indeterminate, and a plausible, experimentally verified MOA explaining such effects without systemic distribution of formaldehyde is lacking.
  ○ The evidence indicates that inhalation of formaldehyde also likely causes reproductive toxicity in men, given sufficient exposure conditions, based on robust evidence in animals that presents a coherent array of adverse effects in two species, and slight evidence from observational studies of occupational exposure. Uncertainties include a lack of well-conducted animal studies testing formaldehyde exposure levels below 6 mg/m^3^ and no plausible, experimentally verified MOA explaining such effects without systemic distribution of formaldehyde; however, some support for indirect effects in rodents is provided by relevant mechanistic changes in male reproductive organs.
- Nervous System Effects
  ○ The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause an increase in incidence or mortality from the motor neuron disease, ALS, given sufficient exposure conditions, based on slight epidemiological evidence. No relevant animal studies (i.e., indeterminate evidence) or mechanistic information were identified, and additional studies are warranted.
  ○ Likewise, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause increases in multiple manifestations of neurobehavioral toxicity, given sufficient exposure conditions, based primarily on slight evidence of effects in animals of two species across several behavioral domains (i.e., neural sensitization; tests of learning and memory; and tests of motor-related behaviors), and supported by slight evidence in human observational and controlled exposure studies. An experimentally verified MOA explaining such effects without systemic distribution of formaldehyde is lacking; however, some mechanistic findings support the potential for indirect effects on relevant brain regions. Well-conducted studies of these potential effects are currently unavailable.
  ○ The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause developmental neurotoxicity, given sufficient exposure conditions, based on slight evidence in animals for neuropathology and potentially supportive mechanistic findings in relevant brain regions. However, as neither an experimentally verified MOA nor relevant studies in children were identified, this is an area in need of further research.

## 4.3 SUMMARY OF CONCLUSIONS FOR CANCER

### “Formaldehyde Is Carcinogenic to Humans by the Inhalation Route of Exposure”^40^

Several lines of evidence support this conclusion. Specifically, the hazard descriptor carcinogenic to humans is independently substantiated by three lines of evidence, namely evidence integration judgments that the evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer, sinonasal cancer and, myeloid leukemia, in exposed humans.

These overall confidence conclusions, as well as the strength of the human and animal evidence (i.e., robust, moderate, slight, indeterminate), were based on the currently available evidence using the approaches described in the description of methods in Section 2 of this report, which included a consideration of mechanistic evidence when drawing each conclusion. Note that, as the site-specific relationship of the animal data to the specific human cancer types involved additional considerations, the inference regarding the relevance of the animal data to each specific human cancer is presented herein as a component of the animal evidence judgments.

#### Conclusion: Carcinogenic to Humans

Three separate evidence integration judgments independently substantiate this conclusion:

- [underlined: Nasopharyngeal cancer]—The evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer (NPC) in humans. This is based primarily on observations of increased risk of NPC in groups exposed to occupational formaldehyde levels and nasal cancers in mice and several strains of rats, with strong, reliable, and consistent mechanistic evidence in both animals and humans (i.e., robust evidence for both the human and animal evidence, and strong mechanistic support for the human relevance of the animal data). The nasopharynx, although not typically specified in animal studies, is the region adjacent to the nasal cavity, where the animal evidence was predominantly observed (thus, the animal evidence is judged as robust). In addition, the evidence is sufficient to conclude that a mutagenic MOA of formaldehyde is operative in formaldehyde-induced nasopharyngeal carcinogenicity.
- [underlined: Sinonasal cancer]—The evidence demonstrates that formaldehyde inhalation causes sinonasal cancer (SNC) in humans. This is based primarily on observations of increased risk of SNC in groups exposed to occupational formaldehyde levels (i.e., robust human evidence) and supported by apical and mechanistic evidence for nasal cancers across multiple animal species. Some uncertainties remain in the interpretation of the animal nasal cavity data as wholly applicable to interpreting human sinonasal cancer (thus, the animal evidence is judged as moderate). While uncertainties remain, the evidence is sufficient to conclude that a mutagenic MOA of formaldehyde is operative in formaldehyde-induced sinonasal carcinogenicity.
- [underlined: Myeloid leukemia]—The evidence demonstrates that formaldehyde inhalation causes myeloid leukemia in humans. This is based primarily on robust human evidence of an increased risk of the occurrence of myeloid leukemia in epidemiological studies among different populations exposed to occupational formaldehyde levels representing diverse exposure settings. The findings from the occupational cohorts are further supported by other studies of human occupational exposure providing strong and coherent mechanistic evidence that formaldehyde exposure is associated with the detection of additional endpoints relevant to LHP cancers, including an increased prevalence of multiple markers of genotoxicity in peripheral blood and myeloid progenitors. Indirect support is also provided by evidence of other systemic health effects (e.g., reproductive or developmental toxicity) and mechanistic evidence indicating changes in immune cell populations and markers of inflammation (e.g., oxidative stress) in the peripheral blood of exposed humans and animals, although the exact pattern of immune-related changes across studies and species was difficult to interpret. Notably, leukemia has not been observed in the two available rodent bioassays of chronic exposure, including one testing both sexes of rats and mice, and the evidence for genotoxicity in the peripheral tissues of exposed rodents is weak, providing indeterminate evidence of LHP cancers in animals. Taken together, it appears that mechanisms yet to be elucidated that do not involve direct interactions of formaldehyde in the bone marrow need to be considered, and that either the mechanistic pathways stimulated by formaldehyde are different in animals or that the existing animal models tested thus far do not characterize the disease process in humans for these cancers. The exact mechanism(s) leading to cancer formation outside of the respiratory tract are unknown.

The remaining evidence relevant to evaluating the potential for formaldehyde inhalation to cause cancer did not contribute to the overall hazard conclusion above, including formal evaluations of the following cancer types:

- [underlined: Oropharyngeal/hypopharyngeal cancer]—The available evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer in humans. This is based primarily on slight human evidence from epidemiological findings and potentially relevant mechanistic changes (e.g., in buccal cells) and supporting slight animal evidence of preneoplastic lesions and mechanistic changes. While cancer site concordance is not required for hazard determination (U.S. EPA, 2005a), given the known reactivity and distribution of inhaled formaldehyde, a lesser level of confidence in the applicability of the animal nasal findings is inferred for this cancer type as compared to NPC or SNC and the evidence overall is not interpreted to provide reasonable support for a MOA.
- [underlined: Multiple myeloma]—The available evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma. This is primarily based on slight human evidence from epidemiological findings. The animal evidence is indeterminate, and the available mechanistic information was not interpreted to be influential, indicating a need for additional study.
- [underlined: Hodgkin lymphoma]— The available evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma. This is primarily based on slight human evidence from epidemiological findings. The animal evidence is indeterminate, and the available mechanistic information was not interpreted to be influential, indicating a need for additional study.
- [underlined: Laryngeal cancer]— All the evidence related to laryngeal cancer was judged as indeterminate; thus, the evidence was inadequate to determine whether formaldehyde inhalation exposure may be capable of causing this cancer type.
- [underlined: Lymphatic leukemia]—All the evidence related to lymphatic leukemia was judged as indeterminate; thus, the evidence was inadequate to determine whether formaldehyde inhalation exposure may be capable of causing this cancer type.

39 For example, in the case of ozone concentrations of 0.1 ppm, a moderately reactive gas, Ginsberg (2008) predicted a five-fold variation in the dose to the deep lung between quiet and heavy breathing conditions for an 8-year-old child.

40 Although not influential to the independent evaluation in this assessment, the hazard conclusion for cancer is consistent with those drawn by other expert review panels (see Appendix G). Formaldehyde was classified as a known carcinogen by the (NTP, 2011) and a Group 1 carcinogen by (IARC, 2006, 2012), both based on evidence for nasal cancers in humans and animals and myeloid leukemia in humans. For nasal cancers, these classifications were also supported by mechanistic evidence sufficient to identify genotoxicity as contributing to cancer development independent of cellular damage and proliferation. In addition, an expert committee convened by the NAS NRC confirmed the conclusions of the NTP 12th RoC and conducted an independent review of the literature through 2013, concluding that formaldehyde is a known carcinogen. The European Union and Health Canada concluded that formaldehyde is a genotoxic carcinogen with a cytotoxic MOA based on nasal cancer evidence (SCOEL, 2017; Health Canada, 2001, 2006; ECHA, 2012).