# 3 EVIDENCE SYNTHESIS AND INTEGRATION

Potential health hazards from the inhalation of formaldehyde were evaluated across multiple health domains, including sensory irritation; pulmonary function; immune system effects, focusing on allergies and asthma; respiratory tract pathology; nervous system effects; reproductive and developmental toxicity; and cancer. Research results for several cancer sites were evaluated, specifically cancers of the upper respiratory tract ([URT]; i.e., nasopharyngeal cancer, sinonasal cancer, cancers of the oropharynx and hypopharynx, laryngeal cancer) and of the lymphohematopoietic system (i.e., Hodgkin lymphoma, multiple myeloma, myeloid leukemia, lymphatic leukemia). The evidence regarding the potential for formaldehyde exposure to cause other cancer types (i.e., lung, non-Hodgkin lymphoma, brain, bladder, colon, pancreas, prostate, skin) were not systematically evaluated because only a few studies reported analyses for these cancer sites (see Appendix B.3.9 for detail). Multiple health endpoints were evaluated within each of these hazard domains using primary research studies in human populations and experimental animals and in supporting mechanistic studies. The mechanistic studies informing all potential respiratory effects were considered and analyzed together due to the potential interdependencies of the mechanisms involved (see Appendix C.7, with supporting documentation in Appendix B.2.6 and B.3.6). The majority of studies evaluating the potential toxicity of formaldehyde inhalation exposure have focused on effects at the portal of entry (POE), primarily the URT, with less research available to inform potential systemic, or nonrespiratory, effects. Although some uncertainties remain, the organization and analyses in the assessment assume that inhaled formaldehyde is not distributed to an appreciable extent beyond the upper respiratory tract to distal tissues (see Section 3.1); thus, it is assumed that inhaled formaldehyde is not directly interacting with tissues distal to the portal of entry (POE) to elicit systemic effects. Thus, the synthesis of the evidence for each identified health endpoint is provided in Section 3.2 for potential respiratory system-related effects (including cancer and noncancer endpoints) and in Section 3.3 for potential nonrespiratory health effects.

## 3.1 TOXICOKINETICS OF INHALED FORMALDEHYDE

Formaldehyde is a respiratory irritant for which the human body has developed several detoxification and removal processes, especially at the site(s) of first contact (i.e., nasal passages for inhalation). Thus, this discussion of the toxicokinetics of inhaled formaldehyde at the POE is organized according to the most likely sites of first contact between inhaled formaldehyde and biological materials, in the context of the known anatomy and potential elimination processes of the respiratory tract tissues. A more comprehensive summary of what is known about the absorption, distribution, metabolism, and excretion of inhaled formaldehyde is provided in Appendix C.1. This section also includes a discussion of published analyses of the potential impact of endogenous levels of formaldehyde produced during normal cellular metabolism on the toxicokinetics of inhaled formaldehyde.

### 3.1.1 Distribution of Inhaled Formaldehyde

Much of what is known about the uptake and distribution of formaldehyde is based on experimental animal studies, primarily in monkeys and rats. Several of the key considerations for evaluating the toxicokinetics of inhaled formaldehyde at the POE in the rat nose are represented schematically in Figure 3-1. Species differences in the structure of the airways and breathing patterns, as well as the composition of the surface epithelium at various nasal locations, are important considerations when interpreting results in experimental animals and extrapolating observations to humans. While the nasal passages in humans are generally similar to those in other mammalian species, one key difference is that humans and nonhuman primates have nasal passages adapted for both oral and nasal (oronasal) breathing, as opposed to obligate nasal breathing in rodents. A second key difference regards the shape and complexity of the nasal turbinates, with relatively simple shapes in humans, and complex, folded patterns in rodents. In general, these differences provide better protection of the rodent lower respiratory tract against inhaled toxicants than is provided to the human lower respiratory tract (Harkema et al., 2006).

Uptake of formaldehyde (defined as retention within the respiratory tract tissue), based on rough estimates determined from the amount of formaldehyde removed from the air, indicates that the vast majority of formaldehyde is removed from inhaled air by the upper respiratory tract (URT) in monkeys (Monticello et al., 1989; Casanova et al., 1991), dogs (Egle, 1972) and rats (Kimbell et al., 2001b; Kerns et al., 1983; Heck et al., 1983; Chang et al., 1983). Further, dosimetric modeling studies in humans have shown close agreement with observations of exposed rodents, namely, that 90−95% of inhaled formaldehyde is deposited in the URT (Yang et al., 2020; Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 2001b). Most recently, Yang et al. (2020) conducted inhalation studies in 120 (70 female and 50 male) healthy human volunteers and measured their absorption of formaldehyde and selected volatile organic compounds. The absorbed formaldehyde C_inh_ – C_exh_ was seen to be linearly related to C_inh_. The slope of this straight line, which expresses a mean deposition rate for the range of concentrations from 2 ppb to 18 ppb was determined to be 0.97, indicating that most of the inhaled formaldehyde is absorbed, on average, at these low concentrations. This is consistent with prior understanding regarding the extent of formaldehyde absorbed. A detailed description of dosimetry modeling efforts in humans, monkeys, and rats is provided in Appendix C.1. As demonstrated in monkeys and rats, and as modeled in humans, a concentration gradient of inhaled formaldehyde follows an anterior-to-posterior distribution, with high concentrations of formaldehyde distributed to squamous, transitional, and respiratory epithelium, and less uptake by olfactory epithelium. Except under exercise conditions or with exposure to high formaldehyde concentrations, very little formaldehyde reaches more distal sites such as the lung. The possibility that more extensive distribution to the LRT may occur when people are regularly breathing through the mouth or when they have an upper respiratory tract infection has not been directly investigated (see Sections 3.2.2 and 3.2.3 for discussions of the available, indirect evidence). Likewise, no specific toxicokinetic studies focusing on the possibility of inhaled formaldehyde distributing to the developing fetus were identified; however, based on current understanding of its reactivity and distribution, it is unlikely that inhaled formaldehyde would reach the developing fetus.

Asgharian et al. (2012) developed a pharmacokinetic model for transport of formaldehyde and other gases in the human lung, across the air-tissue interface towards arterial blood, that explicitly incorporates information on partition coefficient, metabolism, and tissue reactivities (considered as saturable and first-order clearance pathways). This was a substantial improvement over the approach in Overton et al. (2001) that was used for providing formaldehyde dose to the lung in the Conolly et al. (2004) model for extrapolating cancer risk to the human; Overton et al. (2001) did not model the tissue kinetics [and hence the systemic dose] but assumed a constant mass transfer coefficient. There are several noteworthy results from this paper:

– Surface flux rates of formaldehyde appeared to be predictive of local tissue concentrations.
– 97% of the inhaled formaldehyde was absorbed.
– Formaldehyde did not penetrate beyond 60 µm of tissue depth in any breathing scenario, thus predicting that systemic penetration is not likely to take place.
– This model predicted a 25% higher tracheal mass flux of formaldehyde, and correspondingly lesser flux to the deep lung, than Overton et al. (2001). It is important to note that this quantitative result is not relevant to the dose-response modeling in this assessment (see Sections 5.1 and 5.2). While the extrapolation model by Conolly et al. (2004) uses formaldehyde dose to the human lung as input, this model is not used in this assessment and lung cancer is not identified as a hazard (see Section 3.2.5).

Figure 3-1 Schematic of the rat upper respiratory tract depicting the gradient of formaldehyde concentration formed following inhalation exposure, both from anterior to posterior locations, as well as across the tissue depth

Modeling based on observations in rodents predicts a similar pattern of distribution in humans. Drawing is based in part on images by NRC (2011) and Harkema et al. (2006). Note: Other components (e.g., naris, transitional epithelium) have been omitted for clarity.

Corley et al. (2015) developed integrated air and tissue transport models for predicting airway region-specific tissue dose of tobacco smoke in the rat and human, upper and lower, respiratory tracts. Their approach coupled computational fluid dynamics (CFD) models for gas transport in the airways with airway region-specific PBPK models for tissue transport, and included realistic, transient breathing patterns. Although the paper was aimed at tobacco smoke, results were separately provided for the acrolein, formaldehyde and acetaldehyde constituents. Metabolic interactions and reactions were described by clearance through a saturable enzymatic pathway, a first order pathway representing intrinsic tissue reactivity, and a first order binding to DNA to form DPX. Details on regional distribution of metabolic enzymes and local blood perfusion rates were incorporated and the simulations were carried out until breath-by-breath, steady-state kinetics was achieved in all tissues. These calculations of regional tissue concentrations as a function of tissue depth are a substantial improvement over other dosimetry models that could model only airway wall flux rates of formaldehyde. The primary results relevant to this assessment were as follows:

- Formaldehyde does not penetrate deep into epithelial or subepithelial tissue even in the olfactory region where the penetration was greatest, and therefore does not transport directly to the systemic blood circulation at moderate exposure concentrations.
- As with prior formaldehyde rat dosimetry models, their model predicted greatest initial uptake rates of the gas in the anterior respiratory nasal region. However, the uptake was greater in the anterior dorsal olfactory epithelium when area under the curve (AUC) concentrations were calculated by integrating the concentration profile over time of exposure as well as depth normal to the air-tissue interface under more realistic transient breathing profiles.
- The simulation covered only oral inhalation in the human because the purpose of the research was to investigate uptake from cigarette smoke. In the human, oral and laryngeal tissues received the greatest local tissue dose. Overall formaldehyde absorbed was 97% at 2 and 6 ppm and about 94% at 15 ppm exposure concentrations.
- Formaldehyde surface fluxes did not correlate well with local time dependent tissue concentration AUCs for all nasal tissues in the rat; the AUCs were significantly higher in the olfactory region than would be predicted by surface flux alone. This finding was counter to the conclusion in Asgharian et al as detailed above.

The modeling approach in Corley et al. (2015) could potentially make a tangible difference in extrapolated dose over that computed by solely surface flux-based models in the case of reactive gases that result in adverse effects in the rat olfactory region. Because the findings of formaldehyde induced cancer or noncancer effects in the URT of the rat are not observed in the olfactory region (see Section 3.2.5), this modeling approach by Corley et al. (2015) was not applied.

As inhaled formaldehyde enters the URT, it interacts with the mucociliary apparatus, the first line of defense against inhaled materials in the nose. In nasal mucus, most of the formaldehyde is rapidly converted to methanediol (~99.9%) and a minor fraction remains as free formaldehyde (~0.1%) (Bogdanffy et al., 1986). Inhaled formaldehyde induces mucostasis and ciliastasis in the rat that extends from anterior to posterior regions of the nasal cavity depending on the concentration and duration of exposure (Morgan et al., 1986a). Thus, inhalation of higher concentrations can potentially slow clearance mechanisms and increase the proportion of formaldehyde that is available to react with cellular components or that is distributed to epithelium and systemic circulation. Whether mucostasis or ciliastasis is induced with longer exposure duration to low levels of formaldehyde is not known. Methanediol is assumed to be better able to penetrate the tissues while free formaldehyde reacts with macromolecules. It is assumed that the equilibrium is rapid, hence that the methanediol: free formaldehyde equilibrium ratio is maintained (Fox, 1985). Formaldehyde levels are reduced through interactions with components of the mucus and through mucociliary clearance, through reactions with cellular materials at the plasma membrane of the respiratory epithelium, via interactions with glutathione (GSH) and other macromolecules in the intracellular and extracellular space, through localized metabolism and conjugation reactions, and through reversible interactions with intracellular materials. These processes result in the formation of a gradient of formaldehyde across the tissue space, with the greatest formaldehyde concentration at the apical surface of the mucosa, and the lowest levels of formaldehyde at deeper components of the tissue, such as the nasal-associated lymphoid tissues (NALT) and blood vessels.

Several uncertainties exist regarding the transition of inhaled formaldehyde from the mucociliary layer to the underlying epithelium. Although direct experimental evidence is lacking, the biochemical properties of formaldehyde make it likely that inhaled formaldehyde (in the hydrated or anhydrated form) undergoes passive transport, via simple diffusion, across biological membranes. As a result, higher extracellular formaldehyde levels would be expected to result in increased diffusion into the cell owing to the concentration gradient formed. However, this concentration gradient may be affected by endogenous formaldehyde levels, since in humans, as in other animals, formaldehyde is an essential metabolic intermediate in all cells (Thompson et al., 2009).

Two groups of researchers, Schroeter et al. (2014) and Campbell Jr et al. (2020) developed toxicokinetic models of formaldehyde uptake that incorporate the production of endogenous formaldehyde in nasal tissue. Schroeter et al. (2014) revised the fluid dynamic modeling by (Kimbell et al., 2001a; Kimbell et al., 2001b) to explicitly include tissue pharmacokinetics. The Campbell Jr et al. (2020) model simulates observed data for formaldehyde-induced DNA mono-adducts (N^2^-hydroxymethyl-dG) using exogenous and endogenous formaldehyde adduct data published after 2010. This model was based on a modification of Andersen et al. (2010) which simulated formaldehyde-induced DNA-protein cross-links (DPX). Both models, Schroeter et al. (2014) and Campbell Jr et al. (2020), interpreted their modeling results as indicating endogenous formaldehyde to reduce uptake of inhaled formaldehyde from the air phase to the tissue compartment.

In the first model, net desorption of the gas was predicted at exposure concentrations below 1 ppb in humans. While Schroeter et al. (2014) interpreted calculations they made on “net nasal uptake” of formaldehyde as showing a reduction in the uptake of formaldehyde at low concentrations, EPA believes that this mischaracterizes the modeling results. Appendix C.1.12 discusses problems with the net uptake calculations in Schroeter et al. (2014) and notes that examination of that paper’s tabulated results on formaldehyde flux into nasal tissues indicates a process that is linear in the lower concentration range. In the second model developed only for the rat, the model was calibrated with the restriction that formaldehyde absorption in the nose occurs only at exposure concentrations above 0.3 ppm based upon the available experimental DNA adduct data, and the model predicted that the inhalation rate must exceed the tissue clearance rate for formaldehyde to be absorbed by the tissue. The results from both these pioneering projects add to our characterization of uncertainties related to formaldehyde dose-response at low exposures; at sufficiently low levels of exogenous formaldehyde, the contribution of endogenous formaldehyde could become significant. Additionally, when including endogenous formaldehyde in an analysis it is important to incorporate considerations of the large variability in these levels. [The impact of this variability was apparent, for example, from the individual animal data on DNA adducts formed by formaldehyde in Swenberg et al. (2013), kindly made available to EPA by the authors. A number of animals in these data had very high endogenous levels of these adducts; in these animals, the total (endogenous plus exogenous) internal dose even at a low inhaled exposure concentration of 2 ppm, as measured by the level of DNA adducts, was comparable to the mean total internal dose measured in the group of animals exposed at 10 ppm. At this dose, considerable carcinogenicity was observed in animal bioassays in other studies.] There are also crucial uncertainties in the measurements of free endogenous formaldehyde levels as highlighted by Campbell Jr et al. (2020) and discussed further in Appendix C.1.

EPA evaluated the Schroeter et al. (2014) model and determined that the model predicts any external exposure to cause some increase in formaldehyde tissue concentration over background levels. EPA’s evaluation, as detailed in Appendix C.1, pointed to critical uncertainties in model assumptions; therefore, this model was not directly used in EPA calculations. However, as a sensitivity analysis, it was seen that EPA benchmark concentrations based on formaldehyde as a dose metric in Sections 5.1.2 and 5.2.1 do not change appreciably when results from Schroeter et al. (2014) are used.

Extrapolation of results in Campbell Jr et al. (2020) to humans is not possible because the data and the model are specific to rats. These models and a discussion of studies of formaldehyde distribution in the URT are discussed further in context of the toxicokinetics of inhaled formaldehyde in Appendix C.1.

### 3.1.2 Metabolism, Binding, and Removal of Inhaled Formaldehyde

In the URT, formaldehyde is predominantly metabolized by glutathione-dependent class III alcohol dehydrogenase (ADH3) and by a minor pathway involving aldehyde dehydrogenase 2 (ALDH2) to formate. Formate can either enter the one-carbon pool leading to protein and nucleic acid synthesis or is further metabolized to CO2 and eliminated in expired air or excreted in urine unchanged. ADH3 and ALDH2 show region-specific differences in distribution in the respiratory and olfactory mucosa, and higher levels of ADH3 activity have been reported in the cytoplasm of the respiratory and olfactory epithelial cells of rats and in the nuclei of olfactory sensory cells, as compared to other regions of the nasal mucosa (Keller et al., 1990). The presence of areas of high enzyme activity highlights a significant barrier to the penetration of inhaled formaldehyde beyond the respiratory epithelium.

Formaldehyde can interact with macromolecules either by noncovalently binding to glutathione (GSH), tetrahydrofolate (THF), or albumin in nasal mucus or by covalently forming DNA protein crosslinks (DPXs), DNA-DNA crosslinks (DDCs), hydroxymethyl-DNA (hm-DNA) adducts (see Appendix C.1), or protein adducts, such as N6-formyllysine (Edrissi et al., 2013b; Edrissi et al., 2013a). In rats and monkeys, a concentration-dependent increase in DPX formation is observed in nasal passages. Metabolic incorporation studies with 14C-formaldehyde have shown both covalent binding and metabolic incorporation in nasal tissues (Casanova-Schmitz et al., 1984b; Casanova and Heck, 1987). Inhaled formaldehyde induces a concentration-dependent increase in N2-hydroxymethyl deoxyguanosine (N2-hm-dG) adducts, another form of formaldehyde-induced covalent DNA modification, in the nasal passages of monkeys and rats. Recently, analytical methods have been developed that can distinguish between N2-hm-dG adducts from exogenous (inhaled) formaldehyde and N2-hm-dG adducts from endogenous formaldehyde (Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011; Lu et al., 2012). For example, an increase in exogenous formaldehyde adducts has been observed in rat nasal tissue at 0.7–15 ppm (0.86–18.45 mg/m^3^) formaldehyde without any significant increases in endogenous adducts following a single 6-hour exposure (Lu et al., 2011) or at 10 ppm (12.3 mg/m^3^) after exposure to formaldehyde for 1 or 5 days (6 hrs/day) (Lu et al., 2010a). However, in a more recent study with a lower detection limit for adducts and testing lower formaldehyde exposure levels, Leng et al. (2019) did not observe an increase in exogenous hmDNA adducts or DPXs, including in nasal and respiratory tissues as well as at systemic sites (e.g., bone marrow), at formaldehyde levels of 0, 1, 30, or 300 ppb (up to 0.37 mg/m^3^) after exposure for 28 days. The lack of detectable exogenous adducts in the URT at 0.3 ppm (0.37 mg/m^3^) helps to inform the evolving understanding of formaldehyde induced DPX at lower concentrations, which would benefit from additional study. DNA monoadducts (Yu et al., 2015a; Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011) and DPXs (Lai et al., 2016) derived from exogenous formaldehyde were detectable in nasal tissues, but not in distal tissues (including the bone marrow), of experimental animals exposed by inhalation, supporting that exogenous formaldehyde is not systemically distributed. Also, toxicokinetic studies showed that labeled carbon from inhaled formaldehyde measured in bone marrow of rats was the result of metabolic incorporation from the 1-Carbon (1C) pool, not covalent binding, further supporting the lack of transport of formaldehyde or metabolites of formaldehyde to the distal tissues (Casanova-Schmitz et al., 1984b). Finally, inhalation exposure to formaldehyde does not appear to alter blood formaldehyde levels (approximately 0.1 mM across different species), suggesting that inhaled formaldehyde is not significantly absorbed into blood (Kleinnijenhuis et al., 2013; Heck et al., 1985; Casanova et al., 1988).

The toxicokinetics of formaldehyde may be influenced by certain formaldehyde-related effects, such as mucociliary clearance (Morgan et al., 1983), reflex bradypnea (rodents only) and corresponding reductions in minute volume (Chang et al., 1981; Chang and Barrow, 1984), and dynamic changes in tissue structure (Kamata et al., 1997), all of which have the potential to modulate formaldehyde uptake and clearance. For example, during repeated inhalation exposure to formaldehyde, mice but not rats lower their minute volume thereby restricting the intake of the gas (Chang et al., 1981; Chang and Barrow, 1984), which may impact dosimetric adjustment if the dose-response results from these studies are extrapolated to humans. Exposure to formaldehyde can also cause a perturbation of ADH3-dependent pathways involved in cell proliferation (Nilsson et al., 2004; Hedberg et al., 2000), protein modification and cell signaling (Que et al., 2005), S-nitrosoglutathione (GSNO) metabolism, and deregulation of nitric oxide-dependent pathways (Thompson et al., 2010). In rats exposed by inhalation to high concentrations of formaldehyde, a rapid GSH depletion can occur, which may result in more free formaldehyde available for covalent binding and a decrease in metabolic incorporation (Casanova and Heck, 1987).

Assumptions based on what is known about the distribution and metabolism of formaldehyde and its detoxification products allow inferences to be made about how inhaled formaldehyde is eliminated as CO_2_ in expired air or in various forms in urine. Approximately one third of inhaled formaldehyde is estimated to be removed in the URT mucus (Schlosser, 1999). It is expected that the majority of this formaldehyde would be removed from the URT via esophageal clearance and excreted in urine in various forms. A large amount of inhaled formaldehyde penetrating the mucociliary layer of the URT is metabolized in the nasal cavity, giving rise to formate, which can be excreted in urine. Part of this formate may also be further oxidized and eliminated in the exhaled breath as CO_2_. Some formaldehyde is incorporated into the 1C pool and repurposed for protein and nucleic acid synthesis.

## 3.2 EVIDENCE FOR EFFECTS ON THE RESPIRATORY SYSTEM

Research on several noncancer respiratory health effects was synthesized for the following health domains: sensory irritation (see Section 3.2.1), pulmonary function (see Section 3.2.2), immune system effects focusing on allergies and asthma (see Section 3.2.3), and respiratory tract pathology (see Section 3.2.4).

Synthesis of the evidence relevant to potential carcinogenicity at respiratory sites focused on cancers in the upper respiratory tract ([URT]; see Section 3.2.5), as less has been reported concerning cancer associations at other respiratory sites (see Appendix B.3.9 for details).

As previously described, inhaled formaldehyde is highly reactive at the portal of entry (POE), that is, nose and upper airways, which results in alterations to the local tissues that could give rise to respiratory system health effects. The potential noncancer effects involve many of the same biological processes; thus, a high degree of overlap across the mechanistic changes underlying these responses is expected. Similarly, because the potential respiratory health effects are interrelated, effects on one outcome may affect others. Accordingly, an overarching evaluation of the mechanistic information pertinent to any or all potential noncancer respiratory system health effects (some of which is relevant to carcinogenicity) was performed (see Appendix C.7, with supporting documentation in Appendix B.2.6 and B.3.6). The primary mechanistic conclusions drawn from this overarching evaluation are summarized in the MOA analyses in Sections 3.2.1–3.2.4. Section 3.2.3 includes a discussion expanded to include mechanistic changes in nonrespiratory tissues that might relate to respiratory system health effects, although these findings are also relevant to the nonrespiratory (systemic) health effects reviewed in Section 3.3.

Finally, an essential component of the analysis of potential carcinogenicity at respiratory sites involves evaluating whether inhaled formaldehyde causes genotoxicity or mutagenicity. Because abundant information exists on this topic, the data are comprehensively described in Appendix C.3, with the primary conclusions summarized in Section 3.2.5. Some of the conclusions from the genotoxicity evidence analyzed in Appendix C.3 are also relevant to interpretations regarding potential cancers at nonrespiratory (distal) sites in Section 3.3.3.

### 3.2.1 Sensory Irritation

This section describes research on formaldehyde inhalation and sensory irritation in experimental and observational studies in humans. As described in Section 2.2.2, studies describing reports of sensory irritation prevalence based on questionnaire responses or objective measures, such as eye blink frequency or conjunctival redness, were the focus of this review. Although not systematically evaluated, formaldehyde inhalation-induced sensory irritation in animals is a well-established phenomenon (Nielsen et al., 1999; Kane and Alarie, 1977; Chang et al., 1981; Barrow et al., 1983), as summarized in Appendix C.2.

Formaldehyde has been found to be a sensory irritant of the eyes and respiratory tract in several epidemiological studies causing mild to severe symptoms, including itching, stinging, burning, and watering eyes; sneezing and rhinitis; sore throat; coughing; and bronchial constriction. Exposure levels in the residential studies ranged from 0.01 (the limit of detection [LOD] in the available studies) to approximately 1 mg/m^3^, with a large proportion of residences having levels less than 0.1 mg/m^3^. Symptoms of eye irritation were reported at lower concentrations than symptoms of the nose or throat. Many epidemiology studies evaluated symptoms of irritation among residents exposed to formaldehyde in their homes, workers involved in the production or use of formaldehyde products, and anatomy students participating in the dissection of formaldehyde-preserved cadavers. In addition, data from several controlled human exposure studies are available that evaluated acute responses among healthy or asthmatic volunteers during rest or exercise (see Table 3-1). The controlled exposure studies evaluated formaldehyde concentrations above 0.1 mg/m^3^, showing that the irritant response to formaldehyde is an immediate phenomenon apparent at concentrations of 0.1 mg/m^3^, the lowest concentration evaluated, and higher. The irritation resolves when exposure is removed (Sauder et al., 1986; Krakowiak et al., 1998; Andersen, 1979; Andersen and Molhave, 1983). Concentration was related to both prevalence and severity of symptoms. In addition, a large variability in sensitivity to the irritant properties of formaldehyde at specific concentrations was observed (Mueller et al., 2013; Berglund et al., 2012). Because of the wide variability in responses, it has been difficult for experimental studies to characterize the exposure-response relationship in the lower range of concentrations experienced by the general population. Sensory irritation is understood to occur as a result of direct interactions of formaldehyde with cellular macromolecules leading directly or indirectly to stimulation of trigeminal nerve endings; branches of the trigeminal nerve responsible for chemosensation innervate the oral, ocular, and nasal cavities. However, the most notable and well-studied of these is activation within the nasal mucosa (i.e., in the respiratory epithelium) and stimulation in the oral cavity is unlikely to lead to eye irritation or similar symptoms.

Studies in humans provide robust evidence of sensory irritation based on the controlled human exposure studies and observational epidemiology studies, and this effect also is well described and accepted across a range of experimental animal species (robust). Further, there is an established MOA for this well-studied health effect, based primarily on mechanistic evidence in experimental animals, and this MOA is interpreted to be operant in humans. Overall, a judgment was drawn that the evidence demonstrates that inhalation of formaldehyde causes sensory irritation in humans, given sufficient exposure conditions. The primary support for this conclusion is based on residential studies with mean formaldehyde concentrations >0.05 mg/m^3^ (range 0.01 to approximately 1.0 mg/m^3^) and controlled human exposure studies testing responses to concentrations 0.1 mg/m^3^ and above.

#### Human Studies

The following discussion is organized by exposure setting, starting first with evidence from controlled human exposure studies, followed by studies of residential exposure, and then laboratory and occupational studies. Evidence tables for each exposure setting (see Tables 3-1 and 3-2) are organized by level of confidence (high, medium, and low) in the study’s results and then by publication year. Fifteen studies were considered not informative ((Yang et al., 2001; Wei et al., 2007; Wantke et al., 1996a; Thun et al., 1982; Schuck et al., 1966; Sauder et al., 1986; Saowakon et al., 2015; Salonen et al., 2009; Norsted et al., 1985; Lovreglio et al., 2009; Day et al., 1984; Dally et al., 1981; Cometto-Muñiz and Hernández, 1990; Bracken et al., 1985; Akbar-Khanzadeh et al., 1994)). The study evaluations are included in Appendix B.3.2.

##### Controlled human exposure studies (acute exposure)

Controlled human exposure studies testing exposures from less than 1 hour to 5 hours reported slight-to-moderate irritation of the eyes, nose, and throat detected by subjects at formaldehyde concentrations beginning at around 0.3−0.4 mg/m^3^ (see Table 3-1), although the data do not clearly identify the concentration at which symptoms of irritation begin. Eye irritation was reported at lower concentrations than nasal or throat irritation, and symptoms increased in frequency and severity with exposure level.

Both prevalence and severity of symptoms were associated with increasing concentration between 0.12 and 2.5 mg/m^3^ (see Table 3-1). Overall, the prevalence of eye irritation increased from <10 to >80% across several studies with formaldehyde concentrations of 0−4 mg/m^3^ (see Figure 3-2). The prevalence of mild-to-moderate irritation varied among individuals at specific concentration levels. For example, at concentrations above 2 mg/m^3^, prevalence ranged from 53 to 100% (Witek et al., 1987; Schachter et al., 1986; Schachter et al., 1987; Kulle et al., 1987; Andersen and Molhave, 1983). Possible reasons for the variation may include differences in exposure duration or differences in the characteristics of the volunteers (e.g., interindividual variation due to smoking status, prior exposure history, or respiratory health). In addition, one research group reported a much lower symptom prevalence (27%) among healthy and asthmatic subjects exposed to 3.7 mg/m^3^ formaldehyde for 60 minutes (Green et al., 1987); however, this response is not directly comparable to the other studies because the authors only presented irritation prevalence for more severe symptoms (moderate severity or greater). Two high confidence controlled human exposure studies that were also not directly comparable to the studies above used a different metric to measure symptoms, a subjective symptom score using a validated questionnaire (Mueller et al., 2013; Lang et al., 2008). The results of the two studies differed; Lang et al. (2008) reported an increase in symptom scores for eye irritation at 0.3 mg/m^3^, although with control for responses to questions that assessed “negative affectivity,” the association was not observed until 0.5 mg/m^3^, and Mueller et al. (2013) reported no effect related to formaldehyde exposure at concentrations up to 0.86 mg/m^3^. Participants in all of the studies were 18 to 39 years old.

Only a few studies evaluated whether symptom prevalence or severity changed over the course of the exposure period. One research group recruited university volunteers and compared their responses to controlled formaldehyde exposure against responses in hospital laboratory workers with routine exposure to formaldehyde; responses were similar between the two groups during the 40-minute period at 2 ppm (Schachter et al., 1986; Schachter et al., 1987). The study of the laboratory workers was concluded to have medium confidence because some study aspects may have reduced the study’s sensitivity, including that the previous formaldehyde exposure was not characterized, and other characteristics, such as being a smoker, were not controlled. The university volunteers reported the highest symptom scores when subjects first entered the exposure chamber with declines over the 40-minute exposure period. Andersen and Molhave (1983) also found that eye irritation was experienced earlier in the exposure period among subjects exposed to higher concentrations (1 and 2 mg/m^3^) and that symptom severity increased and then plateaued or decreased after 3 hours. However, the initiation of symptoms was delayed at lower concentrations (0.3 and 0.5 mg/m^3^), and symptom severity continued to increase over the rest of the exposure period. Other studies involving exposures from a few minutes to 1 hour also reported irritation responses that slightly decreased or plateaued (Green et al., 1987; Bender et al., 1983). Note that Bender et al. (1983) used a protocol involving exposure to the eyes only, which may involve a different type of response compared to inhalation. Therefore, these few studies suggest that some acclimatization may occur over a few hours at higher concentrations; however, this phenomenon may not be apparent when concentrations are lower (<1 mg/m^3^). Further, based on the few studies available, individuals with long-term occupational exposure to formaldehyde do not appear to respond differently than individuals with no previous known exposure.

Figure 3-2 Prevalence of eye irritation in medium and high confidence controlled human exposure studies of acute formaldehyde exposure

Medium and high confidence studies (all of which randomly assigned the order of exposure levels) are graphed in relation to formaldehyde concentration. The results from Schachter et al. (1987) are graphed in open symbols because subjects were also exposed to formaldehyde through their occupations or cigarette smoke. *The high confidence study included in this graphic provided prevalence only for irritation severity of moderate or greater (as compared to other studies reporting any severity, for example mild or greater). Not included in the graph are three high confidence studies reporting increases in symptom intensity or scores for eye irritation but not reporting prevalence data by formaldehyde exposure level (Mueller et al., 2013; Lang et al., 2008; Green et al., 1989) and one medium confidence study attempting to identify a threshold for irritation based on “sniffs” of formaldehyde (Berglund et al., 2012). Note that the figure does not convey differences in severity scores, which also increased with formaldehyde exposure level.

In addition to subjective reports, some investigators evaluated objective measures, including eye blink frequency, conjunctival redness, and nasal flow and resistance (Mueller et al., 2013; Lang et al., 2008; Andersen, 1979; Andersen and Molhave, 1983). Eye blink frequency was increased at exposure levels above those where subjective symptoms were reported. For example, two studies evaluated responses to a combination of concentration peaks superimposed on a constant formaldehyde exposure (Mueller et al., 2013; Lang et al., 2008). Lang et al. (2008) found that increased eye blink frequency and conjunctival redness occurred at 0.62–1.2 mg/m^3^ among subjects who also reported symptoms of eye irritation at 0.37 mg/m^3^. Mueller et al. (2013) found no exposure-related effect on blinking frequency and conjunctival redness, although total symptom scores increased beginning at 0.37 mg/m^3^ with peaks of 0.7 mg/m^3^ in a group with nasal hypersensitivity. Studies using objective measures of nasal irritation reported variable results including no change in nasal flow and resistance between 0.19 and 0.62 mg/m^3^ (Lang et al., 2008), a decrease in nasal mucus flow at a concentration of 0.37 mg/m^3^ and higher (Andersen and Molhave, 1983), and an increase in nasal flow rate among hypersensitive participants at 0.86 mg/m^3^ (Mueller et al., 2013). Subjects exhibited a large degree of individual variability in sensitivity for both objective and subjective responses (Mueller et al., 2013; Lang et al., 2008; Berglund et al., 2012).

Table 3-1 Summary of controlled human exposure studies of formaldehyde and human sensory irritation

Study and design | Results
Mueller et al. (2013); Design:N = 41, age 32 ± 9.9 years, nonsmoking, healthy male volunteers; categorized into hyposensitive and hypersensitive based on CO_2_ sensitivity measurements in nasal mucosa (cutpoint median 80.3 mm on visual analogue scale [VAS]). Exposure order randomly assigned; repeated measures cross-over design; blinding not described. Five 4-hour exposure conditions, 1 per day, over 5 days. Four 15-minute cycle exercise segments during exposure period.; Outcome: Irritation assessed by conjunctival redness (digital photographs), blinking frequency (blinks counted in 60-second segments from 5-minute video, two counters blind to concentration), tear film break-up time (time to first close of eyelid while staring at mark on wall), nasal flow and resistance (rhinomanometry), and validated symptom questionnaire (SPES German version) measured before exposure and shortly before the end of exposure. Severity rated using VAS with 100-mm scale.; Exposure: 4 hours in groups of 2. Clean air, 0.3 + 4 peaks of 0.6 ppm, 0.4 + 4 peaks of 0.8 ppm, 0.5 ppm and 0.7 ppm (0.0, 0.37 + 0.74, 0.49 + 0.98, 0.62, and 0.86 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported.; Study evaluation: High confidence | Results presented in graphs of difference between pre- and end of test values. Large interindividual variability in scores between subjects for all measures. Blinking frequency and conjunctival redness―no exposure-related effect, tear film break-up time―increased in 0.4/0.8 ppm and 0.5 ppm (p < 0.05), nasal flow rate increased in hypersensitive 0.7 ppm (p < 0.01); total symptom score increased in hypersensitive at 0.3/0.6 ppm (p < 0.001) and 0.4/0.8 ppm (p < 0.01), perception of impure air increased in hypersensitive at all exposure levels (including clean air, 0.01 ppm). Control for “negative affectivity” did not alter associations.; Combined eye symptom score reported to be increased with higher scores among hypersensitives at all exposures except 0.7 ppm (0.86 mg/m^3^). Changes in scores were not statistically significant and no exposure-response was observed (results in online supplemental resource 10 in Mueller et al. (Mueller et al., 2013)). Severity measured using VAS ranged between −0.2 and 2.1 mm).
| SPES Symptom Score (SD)―Eye Irritation
| mg/m^3^ Average/peak | Hyposensitive^a^ | | Hypersensitive^a^
| 0 | −0.17 (2.02) | | 1.96 (7.59)
| 0.37/0.74 | 0.23 (2.65) | | 2.13 (4.71)
| 0.49/0.98 | 0.62 (5.71) | | 1.43 (5.31)
| 0.62 | −0.09 (2.14) | | 1.24 (2.84)
| 0.86 | 0.94 (4.56) | | 0.52 (4.14)
| ^a^Sensitivity categorized as above or below median for nasal sensitivity to CO_2_ irritation.
Lang et al. (2008); Design:N = 21, age 19−39 yrs, nonsmoking, healthy volunteers. Exposure order randomly assigned; double blinded. Ten 4-hour exposure conditions, 1 per day, over 10 days. Three 15-minute cycle exercise segments during exposure period.; Outcome: Irritation assessed by conjunctival redness (digital slit lamp photographs, two scorers), blinking frequency (90-second count from 6-minute video), nasal flow and resistance (rhinomanometry), and symptom questionnaire (SPES German translation) measured before, three times during, and after exposure, and after last exposure day. Rated on 5 levels (0–5).; Exposure: 4 hours in groups of 4. Clean air, 0.15, 0.3, and 0.5 ppm (0.0, 0.19, 0.37, and 0.62 mg/m^3^); additional 0.3 and 0.5 ppm with peaks up to 1.0 ppm (1.23 mg/m^3^).^a^; Additional 0.0, 0.3, and 0.5 ppm with ethyl acetate (EA) introduced as a “mask” for formaldehyde odor.; Formaldehyde generation via thermal depolymerization of paraformaldehyde, quasi-static chamber, analytical concentrations reported.; Study evaluation: High confidence | Blinking frequency, conjunctival redness significantly increased at 0.5 ppm with peaks of 1.0 ppm.; Symptoms: Maximum scores at 195 minutes; eye and olfactory symptom scores were elevated at 0.3 ppm (p < 0.05). With control for “negative affectivity,” eye irritation symptoms significantly associated with 0.5 ppm with EA or 0.5 ppm with peaks. Severity: Average severity scores were less than 2 (“somewhat”).; Nasal irritation: no significant increase in objective measures; symptoms significantly increased at 0.5 ppm and 0.3 ppm with coexposure to EA (also an irritant; p < 0.05).
Green et al. (1989); Design: N = 24, 10 male, mean age 24 ± 0.7 yr. nonsmoking, no history of allergies or hay fever. Random assignment to order of exposure; double blinded. Four 15-min exercise segments in the 2-hr exposure period.; Outcome: Symptoms questionnaire (presence and severity, scored none = 0 to severe = 5) before, and four times during exposure. Testing pre- and during exposure period (approximate 15-min intervals).; Exposure: 2 hr, four exposures over 4 wks, clean air, 3 ppm (3.69 mg/m3)a, 0.5 mg/m3 activated carbon aerosol (ACA), HCHO + ACA.; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported.; Study evaluation: High confidence | Symptom scores presented graphically for 80-min time point. Formaldehyde treatment elevated symptom scores (p < 0.05) at all time points for eye, nasal and throat irritation, odor, chest discomfort. No effect modification by ACA exposure. Average eye irritation scores <1.5 at 80 minutes; similar response at all measurements (20, 50, 80, and 110 minutes).; No separate effect on cough by formaldehyde, but combined formaldehyde and ACA exposure resulted in elevated score for cough at 20 minutes (p < 0.02) and 80 minutes (p < 0.05).
Green et al. (1987); Design:n = 22, mean age 26.9 ± 3.6 years, nonsmoking, no history of allergies or hay fever. Random assignment to order of exposure; single blinded. Two 15-min exercise segments in the 60-min exposure period.; Outcome: Symptoms questionnaire (presence and severity, scored none = 0 to severe = 5) before, and four times during exposure. Testing pre- and during exposure period (approximate 15-min intervals).; Exposure: 60 minute, clean air and 3 ppm (3.69 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported.; Study evaluation: High confidence | Mean symptom scores associated with 3-ppm exposure at all time points, difference from clean air statistically significant for odor, nose or throat irritation, and eye irritation. Individual severity scores ranged from none to severe.
| Prevalence of scores ≥ moderate severity at 3 ppm (p < 0.01)
| | Healthy (%) | | Asthmatic (%)
| Odor | 23 | | 31
| Nose/throat | 32 | | 31
| Eye | 27 | | 19
Berglund et al. (2012); Design:N = 31 healthy volunteers, 52% male, age 24.5 years, nonsmokers. Exposure concentrations randomly presented; blinding not described.; Outcome: Participants evaluated detection of odor and nasal irritation for each “sniff” with forced-choice responses (yes-yes, yes-no, no-yes and no-no). Goal was to identify the concentration at which a participant detected nasal irritation in all (100%) of the 12 presentations.; Exposure: Series of 18 concentrations; 6.36−1,000 ppb (0.0078−1.23 mg/m^3^).^a^; 12 presentations at each concentration plus 72 blanks; 1 sniff in exposure hood (<3 seconds) followed by clean air, 3 sniffs per minute; 36 exposures per each of eight 12-minute sessions over 4 hours.; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported.; Study evaluation: Medium confidence; Blinding not described; Focus on detection threshold rather than symptom prevalence. | None of the 31 participants detected nasal irritation in 100% of 12 presentations at any formaldehyde concentration. 13% false alarms (reports of detection of odor or irritation for blanks). Large variation in individual distributions of percentage detections for nasal irritation vs. log concentration. Authors could not calculate threshold distributions for irritation. See pooled data below (see Figure 5 in paper).
Kulle et al. (1987); Kulle (1993); Design: Group 1 (N = 10), Group 2 (N = 9), nonsmoking healthy, age 26.3 ± 4.7 years, 53% male. Exposure order randomly assigned; Blinding not reported. 3-hour exposures each week, at same time on five occasions. 8-minute exercise segment every half hour during 2-ppm exposure.; Outcome: Symptom questionnaires before and after each exposure, and 24-hours postexposure. Severity was scored none, mild, moderate, severe (0−5).; Exposure: 3 hour, Group 1: 0.0, 0.5, 1.0, or 2.0 ppm (0.0, 0.62, 1.23, 2.46 mg/m^3^)^a^ at rest, and an additional 2.0 ppm with exercise; Group 2: 0.0, 1.0, or 3.0 ppm (0.0, 1.23, or 3.69 mg/m^3^) at rest, and an additional 2.0 ppm with exercise.; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported.; Study evaluation: Medium confidence; Deficiencies in reporting detail regarding blinding and quantitative results | Mean difference in scores before and after exposure period: Linear dose-response (N = 19) for odor and eye irritation, 0, 1, and 2 ppm (p < 0.0001); and nose/throat (Group 2, p = 0.054). Log-linear dose-response for odor and eye irritation, 0, 0.5, 1.0 and 2.0 ppm (Group 1, p < 0.05). Test for nonlinearity not significant. Data presented graphically, prevalence reported in Kulle et al. (1993), Table 3 in the paper.
| Concentration (mg/m^3^) | N (#) | Prevalence (mild/moderate) | SE^a^
| 0 | 19 | 0.05 | 0.050
| 0.62 | 10 | 0 | -
| 1.23 | 19 | 0.26 | 0.101
| 2.46 | 19 | 0.53 | 0.115
| 3.69 | 9 | 1.0 | -
| ^a^Estimated as: SE = sqrt(p*(1-p)/N)
Schachter et al. (1987); Design:N = 15 healthy hospital laboratory workers routinely exposed to formaldehyde as part of their job, age 32 ± 11.3 years, 33.3% male, N = 2 smokers. Random assignment to order of exposure, double blinded. Two dose levels, four exposure conditions, 2 days at rest and 2 days with exercise. One 10-minute exercise segment at 5 minutes in the 40-minute exposure period.; Outcome: Symptoms diary, scores 0−4, at t = 0, t = 30 minutes, and 4−8 hours and 24 hours postexposure.; Exposure: 40 minutes; clean air and 2.0 ppm (2.46 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported.; Study evaluation: Medium confidence; Co-exposure to 2-propanol, potential confounding by smoking | Symptoms during exercise not different from rest.
| Prevalence and scores during rest
| | Concentration (ppm)
| | 0 | | 2
| | # (%) | S^a^ | # (%) | S^a^
| Odor | 7 (46.7) | 10 | 12 (80.0) | 22
| Eye | 0 | 0 | 7 (46.7) | 9
| Nose | 1 (0.07) | 2 | 0 | 0
| Throat | 1 (0.07) | 2 | 0 | 0
| ^a^Total Score Across all Subjects
| Eye Irritation Severity by Exposure, # (%)
| | 0 ppm | | 2 ppm
| Mild | 0 | | 5 (33.3)
| Moderate | 0 | | 2 (13.3)
| Severe | 0 | | 0
Witek et al. (1986); Witek et al. (1987); Design:n = 15 with asthma, ages 18−35 years, nonsmoking. Random assignment to order of exposure; double blinded. Two protocols (at rest and during exercise).; Outcome: Symptoms questionnaire, severity scores (0−4). Testing at beginning and at 30 min during and 4- to 8-hr and 24-hr postexposure.; Exposure: 40 minutes, 0 and 2 ppm (2.46 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported.; Study evaluation: Medium confidence; Co-exposure to 2-propanol | Symptoms during exercise not different from rest.
| Prevalence (%) and severity scores during rest
| | 0 ppm | | 2 ppm
| | # (%) | S^a^ | # (%) | S^a^
| Odor | 5 (33.3) | 7 | 15 (100) | 30
| Eye | 1 (6.7) | 2 | 11 (73.3) | 16
| Nose | 3 (20) | 4 | 7 (46.7) | 10
| Throat | 4 (26.7) | 4 | 5 (33.3) | 6
| ^a^Total severity score across all subjects
| Symptoms reported to have disappeared postexposure.
Witek et al. (1986); Schachter et al. (1986); Design:N = 15 healthy, age 18−35 year, nonsmokers. Random assignment to order of exposure, double blinded. Two protocols (at rest and during exercise), separated by 4 days.; Outcome: Symptoms questionnaire at beginning and at 30 min during exposure and at 8 and 24 hr after exposure, severity scores (0−4).; Exposure: 40 min; clean air and 2 ppm (2.46 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported.; Study evaluation: Medium confidence; Co-exposure to 2-propanol | Symptoms during exercise not different from rest; highest symptom scores at beginning of exposure with decrease by 30 minutes.
| Prevalence (%) and severity scores during rest
| | 0 ppm | | 2 ppm
| | # (%) | S^a^ | # (%) | S^a^
| Odor | 7 (46.7) | 7 | 12 (80.0) | 18
| Eye | 0 | 0 | 8 (53.3) | 12
| Nose | 4 (26.7) | 4 | 6 (40.0) | 7
| Throat | 2 (13.3) | 2 | 4 (26.7) | 4
| ^a^Total severity score across all subjects
| Eye Irritation Severity by Exposure, n (%)
| | 0 ppm | | 2 ppm
| Mild | 0 | | 5 (33.3)
| Moderate | 0 | | 2 (13.3)
| Severe | 0 | | 1 (7)
Andersen (1979); Andersen and Molhave (1983); Design:N = 16 healthy students, age 30−33, 68.8 % male, 31.2% smokers, groups of four over 4 days. Exposure order determined by Latin square design, blinding not described. Testing before (during 2-hour clean air) and two times during exposure.; Outcome: Subjects used a pointer to express the degree of airway irritation (scale 1 to 100) while being exposed.; Exposure: 5 hours; 0.3, 0.5, 1.0 and 2.0 mg/m^3^ (0.24, 0.40, 0.81 and 1.61 ppm respectively).; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations reported as within 20% of target.; Study evaluation:Medium confidence; Variation in exposure concentrations, reporting deficiencies regarding blinding, potential confounding by smoking | Irritation prevalence with clean air was not reported. At end of exposure to 0.3, 0.5, 1.0, and 2.0 mg/m^3^ of formaldehyde; 3, 5, 15 and 15 subjects respectively of the 16 who participated reported conjunctival irritation, dryness in the nose and throat. Smokers were found to be less sensitive than nonsmokers.; Severity: Maximum individual scores ranged from 30 (slight discomfort) at 0.3 mg/m^3^ to 50 (discomfort) at 3 mg/m^3^. After the first 2 hours, discomfort increased during the exposure period at 0.3 and 0.5 mg/m^3^. In two highest concentrations, discomfort reported during first hour, increased to hour 3, then plateaued or decreased.; Eye blinking increased at 2.0 mg/m^3^ (1.70 ppm).; Subjects reported no symptoms the next morning.
Bender et al. (1983); Design: Panels of seven volunteers from Battelle Memorial Institute (age, health status, smoking status, and gender not reported) exposed to clean air and formaldehyde. Individuals who responded to 1.3 and 2.2 ppm formaldehyde were tested.; Order of exposure assignment not reported, blinding not described. Eye-only exposures for 6 minutes.; Outcome: Response time (seconds); proportion of subjects with shorter response time to formaldehyde than to clean air. Subjective score (0−3) when first detected and after 6 minutes.; Exposure: 6 minutes, eye only, 0, 0.35, 0.56, 0.7, 0.9 and 1.0 ppm (0.0, 0.43, 0.69, 0.86, 1.11, and 1.23 mg/m^3^).^a^; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber, analytical concentrations not reported.; Study evaluation: Low confidence; Reporting deficiencies regarding analytical concentrations, random allocation, and blinding. Sample size <10. | Median time to first irritant response decreased with increasing concentration (Cochran’s χ^2^ test for trend). Severity index increased with increasing concentration.
| Proportion with shorter response to formaldehyde compared to clean air
| PPM | Total | Respondents
| PPM | Total | # | %
| 0 | 28 | − | −
| 0.35 | 12 | 5 | 41.7
| 0.56 | 26 | 14 | 53.8
| 0.7 | 7 | 4 | 57.1
| 0.9 | 5 | 3 | 60.0
| 1.0 | 27 | 20 | 74.1*
| *p < 0.05, compared to control

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

Abbreviations: ACA = activated carbon aerosol; ATS = American Thoracic Society; EA = ethyl acetate; HCHO = formaldehyde; NASA = National Aeronautics and Space Administration; S = Symptom score; SPES = symptom questionnaire; UFFI = urea foam insulation.

a Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

##### Studies in residential settings

Three studies investigated the prevalence of irritation symptoms in relation to residential formaldehyde exposure [(Zhai et al., 2013; Liu et al., 1991; Hanrahan et al., 1984); see also (Sexton et al., 1986) for exposure details of Liu et al. (1991)]. Two studies of occupational exposure in mobile trailers (Olsen and Dossing, 1982; Main and Hogan, 1983) are included with this group because the exposure settings (mobile homes with particle board paneling) are similar. Formaldehyde exposure was associated with an increasing prevalence of eye irritation as well as nose and throat irritation (see Table 3-2 and Figure 3-3). One study, Olsen et al. (1982), assessed the severity of symptoms as well as their presence within the previous month using a linear analogue scale. Among those reporting symptoms of eye irritation, a severity at approximately the midpoint of the scale was reported, which is consistent with the mild or moderate severity reported by the controlled human exposure studies. Two studies in residential populations analyzed exposure-response relationships and observed a statistically significant relationship between increasing formaldehyde concentration (from the LOD of 0.01 mg/m^3^ to >0.98 mg/m^3^) and symptoms of irritation using logistic regression models with adjustment for age, gender, smoking behavior and other potential confounders (Sexton et al., 1986; Liu et al., 1991; Hanrahan et al., 1984). Data were collected on symptoms occurring after participants had moved into their homes (Hanrahan et al., 1984) or those that occurred during the week prior to the end of the one-week formaldehyde sampling period (Liu et al., 1991). Although the sampling period used by Hanrahan et al. (1984) was shorter (1 hour), the method was consistent with NIOSH method 3500 (NIOSH, 1994) and was considered to have high accuracy for the 1-hour samples. In addition, the presence of smokers or gas appliances in the home, sources that might contribute to variability in concentrations, was not associated with indoor formaldehyde concentrations. However, the lack of concordance of the one-hour sampling period for formaldehyde with the period of symptom ascertainment assessed by Hanrahan et al. (1984) adds some uncertainty regarding the reported dose-response relationship. Other emissions released from the same sources as formaldehyde that also can contribute to eye irritation, such as phenols from resins in floor or wall coverings or pinene and terpenes from wood products, were not analyzed. However, a strong exposure-response relationship with formaldehyde, as a cumulative measure (ppm-hr) or a 1-hour concentration, was reported by two medium confidence studies, which is unlikely to be explained to a great extent by unmeasured confounding. Although limited by low participation rates, participants were randomly selected for recruitment, and the investigators noted that the characteristics of the respondents and nonrespondents, such as age of housing stock, demographics, and formaldehyde concentrations, were comparable.

Figure 3-3 graphs prevalence of eye irritation (or burning eyes) by formaldehyde concentration reported by high or medium confidence controlled human exposure studies and residential studies. These results are complementary for the most part and indicate a consistent pattern in response to formaldehyde concentrations between 0 and 1 mg/m^3^. As seen in Figures 3-2 and 3-3, the concentration-response curve for eye irritation in the Kulle et al. (1987) study was shifted to the right compared to other studies that evaluated multiple concentration levels.

Other URT symptoms were reported by these studies as well, including irritation of the nose and throat. A study of formaldehyde levels in redecorated homes in China and respiratory symptoms among residents exposed from 1 month to 3 years, reported a higher prevalence of nasal irritation and throat irritation among adults and children at concentrations above 0.08 mg/m^3^ (Zhai et al., 2013). There was also an increased odds ratio for any symptoms of irritation that was independent of other factors including age, gender, smoking in the family, occupation, education, presence of domestic animals, family history of allergy, and ventilation frequency.

Figure 3-3 Prevalence of eye irritation in medium confidence studies of groups exposed to formaldehyde in residential settings and medium confidence controlled human exposure studies

Panel (A): Hollow symbols reflect medium confidence observational studies with formaldehyde exposure in residential settings. The data for Liu et al. (1991) reflect reconstructed exposure information based on (Sexton et al., 1986) as reported in Table 3-2 and Appendix D.1.1. Panel (B): Hollow symbols reflect medium confidence observational studies and closed symbols reflect the medium confidence controlled (intentional) exposure studies for comparison purposes. Two controlled exposure studies from Figure 3-2 are not included as those results are less comparable due to reporting of prevalence of moderate or greater severity only (Green et al., 1987) or formaldehyde exposure through the subjects’ occupations or cigarette smoke (Schachter et al., 1987). SEs were calculated as described in the associated evidence tables or using the formula: SE = sqrt(p*(1-p)/N).

Table 3-2 Summary of epidemiological studies of residential exposures to formaldehyde and human sensory irritation

Study and design | Results
Zhai et al. (2013); Jan 2008–Dec 2009 (China) (prevalence); Population: 186 homes in Shenyang surveyed, homes were decorated in past 4 years and occupied within the past 3 years; randomly selected one adult from each house, plus 82 children (assisted by parents); characteristics of participants were not described.; Outcome: Reported symptoms and disorders via questionnaire Ferris (1978); Exposure: Cited code for indoor environmental pollution control of civil building engineering (GB50325-2001); sampling duration not reported. Samplers in breathing zone in bedroom, living room, and kitchen; N = 558 in 186 homes; exposure groups “polluted” homes: >0.08 mg/m^3^, mean 0.09–0.13 mg/m^3^, range 0.01–0.55 mg/m^3^, in three rooms; nonpolluted ≤0.08 mg/m^3^, mean 0.04–0.047 mg/m^3^.; Analysis: Compared symptom prevalence for children and adults by exposure category (reported p-values); multivariate logistic regression of respiratory system symptoms (all) in children and adults, adjusting for age, gender, smoking in family, occupation, education, ventilation frequency, domestic pets, house facing, family history of allergy, height, weight.; Evaluation:^a^; For analysis of combined symptoms:; Medium confidence; Combined analysis does not distinguish URT irritation symptoms from asthma-related symptoms; Sampling period duration not reported; timing of questionnaire administration in relation to air monitoring uncertain. Although potential confounders were not considered in symptom-specific analysis, the magnitude of the differences is unlikely to be explained by confounders. | Respiratory system symptoms and disorders by exposure group (N = 186 adults, 82 children)
| Symptom | >0.08 mg/m^3^ (%) | | ≤0.08 mg/m^3^ (%)
| Cough, adults | 16.0* | | 4.5
| Cough, children | 25 | | 8.1
| Phlegm, adults | 6.7 | | 3.0
| Phlegm, children | 15 | | 6.7
| Wheeze, adults | 5.0 | | 3.0
| Wheeze, children | 10 | | 6.6
| Nasal irritation, adults | 52.1** | | 16.4
| Odor disorder, adults | 21** | | 3.0
| Throat irritation, adults | 31.9* | | 13.4
| *p < 0.05, **p < 0.01
| Association of formaldehyde exposure with respiratory system symptoms in adults and children (N = 186 adults, 82 children)
| | Odds Ratio | | 95% CI
| Adults^a^ | 2.6 | | 1.8, 3.8
| Children^b^ | 4.3 | | 2.1, 8.8
| ^a^Other statistically significant covariates were ventilation frequency (OR = 1.6) and domestic pets (OR = 1.5)
| ^b^Other statistically significant covariates were ventilation frequency (OR = 1.8) and family history of allergy (OR = 1.9)
Sexton et al. (1986); Liu et al. (1991) (California); Prevalence survey, 1984–1985.; Population: 2,203 randomly selected mobile home occupants recruited 44% response (836 of 1,895 contacted). 1,394 residents in 663 mobile homes in summer and 1,096 residents in 523 mobile homes in winter. 20–64 years of age.; Outcome: Symptoms (occurrence during 1 week prior to end of sampling period) from mailed questionnaire, questionnaire not described.; Exposure: Formaldehyde sampling using passive monitors mailed to participants, 7-day samples, two rooms.; Average concentration: 0.091 (SD 0.069, range <0.01 (LOD)–0.464) ppm in summer and 0.091 (SD 0.052, range 0.017–0.314) in winter. (0.11 (SD 0.095), range <0.012–0.57 mg/m^3^); Cumulative formaldehyde: formaldehyde concentration × hours spent in the residence (ppm-hr).; Analysis: Logistic regression adjusting for age, gender, smoking status, time spent at home, and chronic respiratory/allergy status.; Evaluation:^a^; Medium confidence; Questionnaire not described but outcomes reported without knowledge of formaldehyde levels. Low participation rate but uncertain whether possible selection bias, if any, was nondifferential or differential. | Significant associations with burning/tearing eyes, stinging/burning skin in summer, and burning/tearing eyes, chest pain, sore throat in winter (effect estimates from logistic regression model were not presented).
| Prevalence Burning/Tearing Eyes ( Liu, 1991 )
| ppm-hr | Summer (%) | | Winter (%)
| <7.0 | 13.3 | | 10.8
| 7.0–12 | 17.1 | | 14.7
| >12.0 | 21.4 | | 20.6
| Burning/tearing eyes higher among females in regression models (note: females exhibit a higher background prevalence of dry eye disease; (Farrand et al., 2017))
| Prevalence (p) Burning/Tearing Eyes (EPA reconstruction; see Appendix D.1.1)
| ppm | Summer (p, %) | Winter (p, %) | N (homes) | 95% CI (%)^a^
| 0.0431 | 13.3 | - | 315 | 1.91
| 0.0475 | - | 10.8 | 205 | 2.17
| 0.0906 | 17.1 | - | 192 | 2.72
| 0.0912 | - | 14.7 | 208 | 2.46
| 0.1698 | - | 20.6 | 110 | 3.86
| 0.1943 | 21.4 | - | 156 | 3.28
| ^a^Estimated as: SE = sqrt(p*(1-p)/N)
Hanrahan et al. (1984) (Wisconsin); Prevalence survey, 1979; Population: 61 teenage and adult occupants from 65 of 208 randomly selected mobile homes. Mean age 48 years, 61% female. Participants blinded to exposure status.; Outcome: Current symptoms with occurrence since moving into home from self-administered questionnaire, questionnaire not described.; Exposure: Formaldehyde measurements: 1-hour samples, average of measurements in two rooms.; Median: 0.16 ppm (0.2 mg/m^3^). Range: <0.1 ppm to 0.80 ppm (<0.12 to 0.98 mg/m^3^). Outdoor mean (SD) = 0.04 (0.03) ppm. Windows closed, smoking banned, gas appliances turned off for 30 minutes prior to measurements.; Analysis: Logistic regression adjusting for age, gender, and smoking.; Evaluation:^a^; Medium confidence; Low participation rate, but exposure and demographic characteristics were comparable among respondents and nonrespondents to the health questionnaire. Differential participation in the study based on symptom severity is unknown but cannot be ruled out. Uncertainty regarding correspondence of one hour exposure measurement with period for symptom ascertainment (years); Questionnaire not described but outcomes reported without knowledge of formaldehyde levels. | A statistically significant concentration-response relationship was reported individually for burning eyes and eye irritation; no regression coefficients provided.
| Burning Eyes
| Formaldehyde (ppm) | | Prevalence (%)^a^ | Upper 95% CI (%)^a^ | SE (%)^b^
| 0.1 | | 3.8 | 18 | 7.2
| 0.2 | | 18.2 | 35 | 8.6
| 0.3 | | 36.2 | 55 | 9.6
| 0.4 | | 52.5 | 74 | 11
| 0.5 | | 65.5 | 84 | 9.4
| 0.6 | | 73.5 | 91 | 8.9
| 0.7 | | 80.6 | 94 | 6.8
| 0.8 | | 84.6 | 96 | 5.8
| ^a^Predicted response estimated by EPA from graphical presentation of logistic regression results normalized to mean age (see Appendix D.1.1).
| ^b^Estimated as: SE (%) = (upper 95% CI- central estimate)/1.96
| Formaldehyde concentration not associated with presence of smoker in home or gas appliances. Regression model showed higher prevalence of eye irritation in younger persons.
Olsen and Dossing (1982) (Denmark); Prevalence survey, 1979.; Exposed Population: 66 of 70 employees of seven mobile day care centers (average building age ^~^6 months old) paneled indoors with urea formaldehyde glued particle board; mean age 29 years, 10/90 percentiles 19/40 years. Referent: 26 of 34 employees randomly selected from three control (nonmobile home) centers with no materials containing formaldehyde. Mean age 32 years, 10/90 percentiles 25/38 years. All worked in day care centers for >3 months.; Outcome: Prevalence (yes/no), Severity of symptoms experienced within 1 month measured in centimeters on scale from 0 to 10, “linear” analogue self-assessment method.”; Exposure: Formaldehyde measurements taken after questionnaire study: 2-hour samples in 2–4 locations in the homes. Mean mobile units = 0.43 mg/m^3^ (range 0.24–0.55 mg/m^3^).; Mean referent = 0.08 mg/m^3^ (range 0.05–0.11 mg/m^3^).; Analysis: Prevalence and average impact scores compared.; Evaluation:^a^; Medium confidence; Some uncertainties regarding temporal concordance of exposure (< one day) and symptom assessments (within last month), but not expected to be substantial. Sample size in referent group small. | The average frequency of mucous membrane irritation of eyes, nose, and throat was 3× higher among staff of mobile units vs. stationary institutions (p < 0.01). Symptoms disappeared after end of work.
| Percentage (p) with affirmative answer
| Irritation | Exposed (%)^a^ | SE (%)^b^ | Referent (%)^a^ | SE (%)^b^
| Eye | 56 | 5.93 | 14.6 | 5.24
| Nose/throat | 74 | 6.06 | 25 | 7.43
| ^a^Estimated by EPA from bar chart in Figure 1 in the paper.
| ^b^Estimated as: SE = sqrt(p*(1-p)/N)
Ritchie and Lehnen (1987) (Minnesota); Prevalence survey, 1979; Population: Over 2000 occupants residing in 900 mobile and conventional homes referred by physician to health department for formaldehyde monitoring.; Outcome: Symptom prevalence reported by interview administered at time of air monitoring.; Exposure: Area samples; average of 30-min samples in 2 rooms. Bedroom mean: Mobile homes 0.43 mg/m^3^, Conventional 0.15 mg/m^3^, range 0.012 (LOD) to 6.79 mg/m^3^.; Analysis: Logistic regression using formaldehyde concentration categorized in 3 levels (< 0.12 mg/m^3^, 0.12 - 0.36 mg/m^3^, > 0.36 mg/m^3^), by age, smoking status, and sex.; Evaluation:^a^; Low confidence (↑); Potential selection based on exposure and outcome status. | Eye Irritation Prevalence (% (SE); N))
| Mobile Homes (by smoking status)
| mg/m^3^ | | Active | Passive | Non-smoker
| < 0.12 | | 2 (1.6) | 1 (0.9) | 1 (0.8)
| < 0.12 | | N = 36 | N = 46 | N = 53
| < 0.12 | | 32 (4.8) | 20 (3.8) | 18 (2.9)
| − 0.36 | | N = 65 | N = 69 | N = 126
| >0.36 | | 93 (1.5) | 88 (2.3) | 86 (2.2)
| >0.36 | | N = 143 | N = 133 | N = 180
| Conventional Homes (any smoking status)
| < 0.12 | | 1 (0.5); N = 695
| < 0.12 − 0.36 | | 12 (1.7); N = 380
| >0.36 | | 89 (3.5); N = 81
| Nose and Throat Irritation Prevalence (% (SE); N)
| Mobile Homes (by smoking status)
| mg/m^3^ | | Active | Passive | Non-smoker
| < 0.12 | | 8 (3.1) | 10 (4.2) | 5 (2.1)
| < 0.12 | | N = 36 | N = 17 | N = 34
| < 0.12 - 0.36 | | 25 (4.2) | 30 (6.5) | 17 (3.1)
| < 0.12 - 0.36 | | N = 65 | N = 24 | N = 93
| > 0.36 | | 85 (2.6) | 88 (3.1) | 78 (3.2)
| > 0.36 | | N = 143 | N = 65 | N = 132
| Conventional Homes (by smoking status and age)
| Age 7 – 54 years
| < 0.12 | | 4 (1.3) | 2 (1.0) | 2 (0.6)
| < 0.12 | | N = 83 | N = 84 | N = 274
| < 0.12 - 0.36 | | 23 (4.4) | 15 (4.0) | 12 (2.2)
| < 0.12 - 0.36 | | N = 59 | N = 50 | N = 160
| > 0.36 | | 86 (4.6) | 79 (6.5) | 74 (6.7)
| > 0.36 | | N = 17 | N = 16 | N = 21
| Age 55+ years
| < 0.12 | | 7 (2.8) | 5 (2.0) | 4 (1.3)
| < 0.12 | | N = 17 | N = 15 | N = 64
| < 0.12 - 0.36 | | 36 (8.8) | 25 (8.4) | 20 (5.7)
| < 0.12 - 0.36 | | N = 9 | N = 1 | N = 19
| > 0.36 | | 92 (3.5) | 87 (5.6) | 84 (6.0)
| > 0.36 | | N = 3 | N = 2 | N = 7
Main and Hogan (1983); Prevalence survey; Population: 21 exposed individuals working in two mobile trailers for 34 months (mean [SD] age 38 [9] years, 76% male); 18 referent staff members who did not work in the trailers (mean [SD] age 30 [6] years, 50% male); Outcome: Modified ATS questionnaire; Exposure: Three 1-hour area samples taken on four occasions (August, September, December, April) always on a Monday. At least one sample was taken from each office in both trailers.; Concentration range 0.12–1.6 ppm (0.15–1.97 mg/m^3^)^a^; Analysis: Group comparisons, χ^2^ statistic; Evaluation:^a^; Low confidence; Potential dissimilarity between comparison groups; more exposure to ETS among referent; small sample size increased potential for unreliable results. Uncertainty regarding participant recruitment process or participation rate. Responses among exposed likely not blinded to exposure status. | Symptom Prevalence While at Work:
| Symptom | | Exposed (n = 21) | Referent (n = 18) | χ^2^ (p-value)
| Eye irritation | | 0.71 | 0.0 | 20.9
| Eye irritation | | 0.71 | 0.0 | (<0.001)
| Nasal symptoms | | 0.33 | 0.0 | 7.3
| Nasal symptoms | | 0.33 | 0.0 | (0.01)
| Throat irritation | | 0.48 | 0.0 | 11.5
| Throat irritation | | 0.48 | 0.0 | (0.001)

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

LOD = limit of detection; RD50 = concentration resulting in a 50% reduction in the respiratory rate; RIL = recommended indoor limit; VOC = volatile organic compound.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.2).

Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Laboratory and occupational exposure

The studies of anatomy students and formaldehyde-exposed workers provide further evidence that formaldehyde exposure is associated with symptoms of eye, nose, and throat irritation. These studies are summarized in tables in the appendix for sensory irritation (Appendix C.4). Exposure levels experienced during anatomy laboratory courses and in occupational settings were high and variable. Formaldehyde levels during anatomy courses generally averaged 0.9 mg/m^3^ and above during the lab, with short-term peaks above 5 mg/m^3^ (Wantke et al., 2000; Uba et al., 1989; Takahashi et al., 2007; Kriebel et al., 1993; Kriebel et al., 2001). These exposures were episodic, one to two sessions per week, for 1−4 hours. Study designs that analyzed reported symptoms and formaldehyde levels measured in close temporal proximity were considered less subject to information bias. The intensity of symptoms (Kriebel et al., 2001) and prevalence or frequency of occurrence (Wantke et al., 2000; Takigawa et al., 2005) of symptoms was related to exposure during the lab. Over time, the magnitude of the increase in symptoms during a laboratory session was reported to decline over the succeeding weeks of the course (Kriebel et al., 1993; Kriebel et al., 2001). Kriebel et al. (2001) modeled average formaldehyde concentration during each lab session in relation to irritation symptoms (separate models for eye, nose, and throat irritation) and reported that intensity of eye irritation symptoms increased by 1.22% per unit increase in ppm, and the magnitude of the increase in intensity declined with each successive week during the course.

Formaldehyde concentrations in the workplace varied by industry. Examples of industrial formaldehyde levels include mean levels of 0.26 mg/m^3^ in a formaldehyde-producing plant in Sweden (Holmström and Wilhelmsson, 1988), 0.96 mg/m^3^ in a melamine formaldehyde resin-producing plant (Neghab et al., 2011) in Iran, and 1.04 mg/m^3^ in a particleboard plant (Horvath et al., 1988). Excursions above 2 mg/m^3^ were measured in some industries. Most of the studies compared responses in exposed groups to those in a referent group, and symptoms of URT and eye irritation were associated with exposure status in these studies. One study also reported a strong exposure-related trend for burning nose, stuffy nose, burning eyes, itchy nose, sore throat, and itchy eyes in multiple regression models, although quantitative results were not reported (Horvath et al., 1988).

##### Summary of Human Evidence Synthesis Judgments

The following factors, in particular the strong consistency and observed dose-dependence, were influential to the synthesis judgment that the human studies on sensory irritation provide robust evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: Increases in sensory irritation of the eye, nose and throat from formaldehyde exposure were consistent across 10 high and medium confidence studies involving acute controlled exposure and four medium confidence studies of symptom prevalence in residential settings. This evidence is supported by consistent findings from several studies with longitudinal designs following formaldehyde exposure in laboratory or occupational settings.
- Dose-Response: Demonstrated exposure-response trends for symptom prevalence and symptom severity were observed in multiple studies.
- Coherence: Different manifestations of irritation, including various symptoms and objective measures, were observed.

In addition to the judgment above, a general inference can be drawn based on the human studies. Specifically, although the evidence base does not completely address the uncertainties associated with such an observation, the currently available studies indicate that the irritant effects of formaldehyde do not appear to appreciably worsen with longer formaldehyde exposures.

#### Animal Studies

##### Summary of Animal Evidence Synthesis Judgments

Although not formally synthesized, the wealth of data for this effect in animals is inferred to provide robust evidence for formaldehyde inhalation exposure-induced effects on sensory irritation. As previously described, the sensory irritant effects of formaldehyde in animals represent a well-established phenomenon (see Summary in Appendix C.2). In addition, the mode of action information (discussed below) describing how formaldehyde inhalation can cause sensory irritation is primarily based on experimental studies in animals, supporting the biological plausibility of the animal evidence and reinforcing this judgment.

#### Evidence on Mode of Action

Sensory irritation is understood to occur as a result of direct interactions of formaldehyde with cellular macromolecules i leading directly or indirectly to stimulation of trigeminal nerve endings; branches of the trigeminal nerve responsible for chemosensation innervate the oral, ocular, and nasal cavities. However, the most notable and well-studied of these is activation within the nasal mucosa (i.e., in the respiratory epithelium) and stimulation in the oral cavity is unlikely to lead to eye irritation or similar symptoms. While other mechanistic changes (e.g., oxidative stress; airway inflammation; damage or dysfunction of the respiratory epithelium) and biological differences (e.g., tissue morphology; underlying allergy, infection, or other respiratory conditions) are expected to be strong modifiers of this sequence of events, the pathway leading to stimulation of trigeminal nerve endings is likely to be the dominant mechanism by which formaldehyde exposure causes sensory irritation. The primary evidence for this conclusion includes mechanistic changes in the URT, which are supported by robust or moderate formaldehyde-specific data (see summary interpretations in Figure 3-4 and Table 3-3; Appendix C.7 includes additional details and evidence supporting other relevant mechanistic changes, some of which are discussed briefly below), and the relationships described are largely well understood biological phenomena, or they have been demonstrated following formaldehyde exposure. Access of airborne formaldehyde to other chemosensory afferents (e.g., in the eye) is expected to contribute to this response. This mechanistic understanding provides strong support for the biological plausibility of this effect. Although the primary support for an MOA reliant on stimulation of receptors on nasal trigeminal nerve endings is from studies in experimental animal models, the mechanistic events presumed to be driving sensory irritation after formaldehyde exposure are expected to be conserved in humans.

Figure 3-4 Possible mechanistic associations between formaldehyde exposure and sensory irritation

An evaluation of the formaldehyde exposure-specific mechanistic evidence informing the potential for formaldehyde exposure to cause respiratory health effects (see Appendix C.7 for clarifying details) identified this sequence of mechanistic events as likely to be the dominant mechanism by which formaldehyde inhalation could cause sensory irritation.

As illustrated in Figure 3-4, formaldehyde exposure appears to result in activation of chemosensory afferents, likely trigeminal nerve C fibers, including in the URT, presumably in the anterior third of the nasal cavity, based on the pattern of chemosensory activation and consistent with the distribution of inhaled formaldehyde (see Appendix C.7). This activation (which can also occur in the eyes) initiates central signals that result in the burning sensation characteristic of sensory irritation. The rapid detection of these sensations in exposed individuals, as well as insights from other irritants, suggest a receptor-mediated event that is dependent on formaldehyde penetration to the nerve endings, which may not have an exposure duration threshold. Thus, mechanisms that prevent access of formaldehyde to these sites^16^, or that reduce the number or response of receptors at these sites, would be expected to reduce such irritant responses. In vitro and ex vivo studies suggest that activation of the trigeminal nerve by formaldehyde is mediated, at least in large part, through cation channels, primarily the Transient Receptor Potential A1 channel (TRPA1). Alongside the centrally mediated physiological response, the initial activation of the trigeminal nerve is also known to cause a localized release of neuropeptides, such as substance P, from nerve terminals (not shown in Figure 3-4), which can affect local inflammatory and immune responses. Observations of these local neuropeptide changes have been reported at slightly higher formaldehyde levels than those shown to activate the trigeminal nerve, generally at >1 mg/m^3^, although the data suggest that they too may be dependent on TRPA1 activation. All of these direct and indirect interactions could act independently or together in a concentration- and duration-dependent manner.

While the response to some irritant chemicals exhibits desensitization or fading of the irritant response over time (e.g., through receptor downregulation) (Nielsen, 1991), it is not clear this is the case with formaldehyde. As previously discussed, results from acute, controlled human exposure studies indicate that some acclimatization may occur over exposures of a few hours at higher concentrations; however, this reduction in symptoms is less apparent (or may be absent) when concentrations are lower (<1 mg/m^3^), and changes to this response pattern in humans over time, particularly with exposure longer than 1 day, remain poorly tested. Studies of reflex bradypnea in rodents (see Appendix C.2), a phenomenon dependent on the activation of the trigeminal nerve, show that repeated exposure for up to a month elicits a similar level of activation of this pathway. However, uncertainties with the rodent data include a nonconstant exposure (i.e., there is at least partial recovery from the reflex effects in rodents with continued exposure in acute studies of minutes to hours, while the available short-term studies employed work hour-like exposure periodicity) and testing only at reflex bradypnea-inducing levels (e.g., >1 mg/m^3^). It is unclear whether the results based on acute or episodic exposures apply to long-term responses to constant oronasal exposure in humans (who do not exhibit reflex bradypnea) at lower formaldehyde levels.

Sensitivity (i.e., the threshold for activation of this pathway) is expected to vary between individuals due to differences in TRPA1 channel sensitivity or access of formaldehyde to TRPA1 channels, as might occur due to differences in tissue structure, mucus production, or TRPA1 channel density in the airways or eyes. Thus, enhanced irritation could plausibly occur directly as a result of sensitization of the receptors to formaldehyde with prolonged exposure or due to the accumulation of other factors that could reduce the threshold for TRPA1 activation by formaldehyde, or indirectly by increased access of formaldehyde to trigeminal nerve endings, for example following damage to juxtaposed epithelial cells or reduced mucociliary function. Airway inflammation has been shown to reduce the threshold for activation of afferent fibers, through an unknown mechanism (Carr and Undem, 2001), and lipid peroxidation byproducts can independently stimulate sensory nerve activation. These latter possibilities are of particular relevance, as exposure to formaldehyde (possibly even at lower levels, e.g., <1 mg/m^3^) appears to result in airway inflammation and increased oxidative stress. Conversely, other modifications to the respiratory epithelium following formaldehyde exposure (e.g., at levels causing effects such as squamous metaplasia, which is generally observed in animals at ≥2.5 mg/m^3^; see Section 3.2.4) could plausibly result in a decreased access of formaldehyde to receptors at trigeminal nerve endings. However, while the structure and function of the URT across species is similar, interpretation of compensatory or adaptive changes within the human URT following long-term exposure based on findings in experimental animals is difficult to infer, and modification of sensory nerve signaling in the context of these important scenarios has, for the most part, not been directly tested. In addition, studies of related chemicals suggest that human sensitivity may also be dependent on demographic factors such as age, gender (women are generally more sensitive), and allergy status (Shusterman, 2007; Hummel et al., 2003), complicating an understanding of changes in sensitivity. While additional studies clarifying modifications to the sensitivity of this pathway with longer-term exposure or under different exposure scenarios would be useful, it is likely that rodents acutely exposed to ~0.2 mg/m^3^ formaldehyde under normal conditions would exhibit sensory irritation, and exposed humans are expected to be more sensitive.

Table 3-3 Mechanistic evidence most informative to the occurrence of sensory irritation after formaldehyde inhalation

Endpoint | Endpoint-specific findings and confidence | | Summary of evidence | Conclusion
↑ URT Oxidative Stress | High or Medium | Human: Increased nasal epithelial M1dG adducts (oxidative stress and lipid peroxidation marker) (Bono et al., 2016): unknown duration (but likely years) at >0.066 mg/m^3^ | Direct and indirect evidence of elevated reactive oxygen species (ROS), possibly at low concentrations (e.g., at >0.066 mg/m^3^; maximum of 0.444 mg/m^3^) with prolonged human exposure | Moderate
↑ URT Oxidative Stress | High or Medium | Animal: mRNA changes indicating increased stress-response proteins (Andersen et al., 2008): short-term exposure at ≥2.46 mg/m^3^ | Direct and indirect evidence of elevated reactive oxygen species (ROS), possibly at low concentrations (e.g., at >0.066 mg/m^3^; maximum of 0.444 mg/m^3^) with prolonged human exposure | Moderate
↑ URT Oxidative Stress | Low | Human: Increased nasal lavage nitrites (Priha et al., 2004): acute (8-hr shift) exposure at 0.19 mg/m^3^ | Data suggest elevated oxidative stress at very low formaldehyde concentrations with acute and short-term exposure | Moderate
↑ URT Oxidative Stress | Low | Animal: Increased glutathione peroxidase and/or nonprotein sulfhydryl groups (Cassee and Feron, 1994; Cassee et al., 1996): shortterm (3 d) duration at 3.94 and 4.43 mg/m^3^, respectively | Data suggest elevated oxidative stress at very low formaldehyde concentrations with acute and short-term exposure | Moderate
TRPA1 Stimulation | High or Medium | Human: None | Indirect data identify TRPA1 as a molecular target for formaldehyde exposure-induced sensory effects | Moderate (data are primarily from acute or shortterm exposure)
TRPA1 Stimulation | High or Medium | Animal: Formaldehyde and related chemicals such as acrolein activate the trigeminal system in wild-type mice, but not TRPA1 knockout mice following acute exposure, at least at high exposure levels (Yonemitsu et al., 2013); taken together with the established role for TRPA1 in acrolein-induced sensory effects (e.g., (Bautista et al., 2006)), these data indirectly support a role for TRPA1 in sensory nerve-related changes following formaldehyde exposure | Indirect data identify TRPA1 as a molecular target for formaldehyde exposure-induced sensory effects | Moderate (data are primarily from acute or shortterm exposure)
TRPA1 Stimulation | Low | Human: None | Indirect data identify TRPA1 as a molecular target of formaldehyde exposure with acute or short-term exposure; inhibitor studies demonstrate that downstream effects of sensory nerve stimulation depend on TRPA1 stimulation | Moderate (data are primarily from acute or shortterm exposure)
TRPA1 Stimulation | Low | Animal: Formaldehyde activates TRPA1 in in vitro and ex vivo models relevant to acute inhalation exposure of the URT and upper LRT (Mcnamara et al., 2007; Luo et al., 2013), and is well established in in vivo models using formalin as a pain stimulus (not a focus of this review); inhibition of TRPA1 channels localized to sensory nerve endings reduces formaldehyde exposure-induced nerve currents in rat trachea (Luo et al., 2013) and immune-related responses in mice (Wu et al., 2013; Lu et al., 2005) with short-term (2- or 4-week) exposure at 1 or 3 mg/m^3^ | | Moderate (data are primarily from acute or shortterm exposure)
Trigeminal Nerve Stimulation | High or Medium | Human: None | Increased activity of trigeminal nerve afferents at <0.5 mg/m^3^ following acute exposure in anesthetized rats | Robust (data are primarily from acute exposure)
Trigeminal Nerve Stimulation | High or Medium | Animal: Increased afferent nerve activity (Tsubone and Kawata, 1991): acute duration exposure resulted in ^~^20% at 0.62 mg/m^3^ and ^~^50% at 2.21 mg/m^3^; (Kulle and Cooper, 1975): acute exposure (threshold detection at 25 seconds) at 0.31 mg/m^3^ | Increased activity of trigeminal nerve afferents at <0.5 mg/m^3^ following acute exposure in anesthetized rats | Robust (data are primarily from acute exposure)
Trigeminal Nerve Stimulation | Low | Human: None | Supportive indirect evidence from ex vivo and in vitro experiments | Robust (data are primarily from acute exposure)
Trigeminal Nerve Stimulation | Low | Animal: Indirect evidence: with acute exposure, dose-dependent increase in nerve currents and Cl^-^ release in intact rat trachea (Luo et al., 2013), and stimulation using in vitro neuronal preparations (Mcnamara et al., 2007; Kunkler et al., 2011) | Supportive indirect evidence from ex vivo and in vitro experiments | Robust (data are primarily from acute exposure)

##### Summary of Inferences Regarding Mode of Action

Robust and moderate evidence for important mechanistic events identifies stimulation of the trigeminal nerve as the dominant MOA. This MOA is assumed to be relevant to sensory irritant effects in humans based on similarities in the systems mediating the identified MOA across species. The identified MOA highlights large variations in sensitivity across individuals, depending on features such as tissue health and physiology, including altered mucociliary function in the nasal cavity, that could influence the stimulation of key receptors (e.g., TRPA1).

#### Evidence Integration Summary

Symptoms of sensory irritation were consistently reported by studies of formaldehyde exposure in multiple exposure settings, and both prevalence and severity of symptoms increased with the level of exposure. Sensory irritation is an acute phenomenon, and symptoms resolve when exposure is removed (Sauder et al., 1986; Andersen, 1979; Andersen and Molhave, 1983). Irritation of the eyes was reported to occur at lower concentrations compared to irritation of the nose or throat (Mueller et al., 2013; Lang et al., 2008). The irritant effects of formaldehyde on the eyes and URT were reported by several controlled human exposure studies that evaluated responses among healthy or asthmatic volunteers using relatively high formaldehyde concentrations (0.12 and 3.7 mg/m^3^) during rest or exercise. In addition to subjective reports, some investigators evaluated objective measures, including eye blink frequency, conjunctival redness, and nasal flow and resistance (Mueller et al., 2013; Lang et al., 2008; Andersen, 1979; Andersen and Molhave, 1983). Eye blink frequency was increased at exposure levels above those where subjective symptoms were reported. Symptoms of sensory irritation also were documented in the epidemiological literature among residential and occupational populations, and students exposed in anatomy classes. Exposed groups described eye, nose, and throat symptoms with formaldehyde exposure, including itching, stinging, burning, and watering eyes; sneezing and rhinitis; sore or dry throat; and coughing. Average formaldehyde concentrations for exposed populations were 0.9 mg/m^3^ (median) among anatomy students (Kriebel et al., 1993), > 0.3 mg/m^3^ among occupational groups (Neghab et al., 2011; Horvath et al., 1988; Holmström and Wilhelmsson, 1988), and 0.2 mg/m^3^ and lower among residential populations (Zhai et al., 2013; Liu et al., 1991; Hanrahan et al., 1984). A statistical exposure-response relationship for the prevalence of eye irritation or burning eyes was described using regression models in some studies (Liu et al., 1991; Kulle et al., 1987; Kriebel et al., 1993; Kriebel et al., 2001; Horvath et al., 1988; Hanrahan et al., 1984). Alternative explanations for these symptoms can be ruled out since there is strong evidence from controlled human exposure studies and residential studies, with exposure-response trends that were adjusted for potential confounders, including age, gender, and smoking. Coexposures in homes, such as that from terpenes, phenol, and acetaldehyde, which are emitted from wood products, carpets and wall coverings, and combustion, were present at lower levels compared to those of formaldehyde. Sensory irritation also was reported among groups in exposure settings without those coexposures (e.g., controlled human exposure studies, anatomy labs). NO_2_, which is emitted from gas stoves, has not been correlated with formaldehyde levels in homes (Mullen et al., 2015).

The magnitude or severity of symptoms does not appear to worsen over periods of prolonged exposure, and some studies have observed decreases over observation periods lasting a few weeks. However, change in responses over time has been examined in only a few studies. Notably, controlled human exposure studies involving occupationally exposed individuals did not observe responses that were less sensitive than those among subjects with no occupational exposure, suggesting that the response persists even with prolonged exposure. Controlled human exposure studies that examined change in response during exposures at relatively high levels (>1 mg/m^3^) reported higher symptom scores initially with subsequent declines suggestive of acclimation during exposure (Schachter et al., 1986; Green et al., 1987; Andersen and Molhave, 1983). However, at lower concentrations (0.3 and 0.5 mg/m^3^), the initiation of symptoms was delayed, and symptom severity continued to increase during the exposure period (Andersen and Molhave, 1983). Overall, these few studies suggest that some acclimatization may occur over a few hours at higher concentrations; however, this phenomenon may not be apparent when concentrations are lower (<1 mg/m^3^).

Stimulation by formaldehyde of sensory nerve endings, predominantly in the URT (but also possibly in the eyes) and presumably involving activation of TRPA1 ion channels on C fibers of the trigeminal nerve, is likely to be the dominant MOA for the observed effects on sensory irritation. It is expected that differences in tissue anatomy and respiratory health status would be strong modifiers of this MOA.

In conclusion, studies in humans provide robust evidence based on the controlled human exposure studies and observational epidemiology studies, robust evidence exists supporting an effect in animals (this phenomenon is well described and accepted across a range of experimental species), and there is an established MOA based on mechanistic evidence in animals (the identified MOA is interpreted to be operant in humans). Overall, the evidence demonstrates that inhalation of formaldehyde causes sensory irritation in humans, given sufficient exposure conditions. The primary support for this conclusion is based on well-conducted residential studies with mean formaldehyde concentrations >0.05 mg/m^3^ (range 0.01 to approximately 1.0 mg/m^3^) and controlled human exposure studies testing responses to concentrations 0.1 mg/m^3^ and above (see Table 3-4).

Table 3-4 Evidence integration summary for effects of formaldehyde inhalation on sensory irritation

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Human | Consistency and Study Confidence | - Four medium confidence studies of symptom prevalence (eye, nose, throat) among adults and children in residential settings (mean >0.05 mg/m^3^ formaldehyde, range 0.01 to approximately 1.0 mg/m^3^); - Consistent findings from several studies involving acute controlled exposure; - Consistent findings in studies with longitudinal designs (e.g., occupational, panel studies of medical students) | | Robust; Based primarily on consistent and dose-dependent findings across residential, controlled acute exposure, and longitudinal studies | The evidence demonstrates that formaldehyde inhalation causes sensory irritation in humans given sufficient exposure conditions^a^; Primarily based on robust human evidence from well-conducted residential studies with mean formaldehyde concentrations >0.05 mg/m^3^ and controlled human exposure studies testing ≥0.1 mg/m^3^. Strong supporting evidence exists, including established mechanistic understanding; Potential susceptibility: Potentially large variations in sensitivity are expected, depending primarily on differences in nasal health (including allergy or inflammatory status) and underlying physiology, but also age and sex
Human | Strength and Precision | N/A | | Robust; Based primarily on consistent and dose-dependent findings across residential, controlled acute exposure, and longitudinal studies
Human | Dose-Response | - Consistent and clear exposureresponse trends in numerous studies | | Robust; Based primarily on consistent and dose-dependent findings across residential, controlled acute exposure, and longitudinal studies
Human | Coherence | - Different manifestations of irritation, including various symptoms and objective measures, were observed | | Robust; Based primarily on consistent and dose-dependent findings across residential, controlled acute exposure, and longitudinal studies
Human | Biological Plausibility | No directly relevant human mechanistic studies were found | | Robust; Based primarily on consistent and dose-dependent findings across residential, controlled acute exposure, and longitudinal studies
Animal | Although animal studies were not formally evaluated, formaldehyde inhalation-induced sensory irritation in rodents is a well-documented phenomenon (see Appendix C.2) | | | Robust
Animal | Biological Plausibility | - Understanding of the MOA underlying the development of sensory irritation following formaldehyde inhalation is primarily based on experimental studies in animals | | Inferred as a well-defined phenomenon with established biological understanding
Other inferences | - Relevance to humans: The effect was observed in humans (robust evidence); - MOA: Robust and moderate evidence for mechanistic events from animal studies identifies stimulation of the trigeminal nerve as the dominant MOA. This is assumed to be relevant to humans based on similarities in systems mediating the identified MOA across species; - Other: This effect does not appear to worsen with longer exposure durations, although some uncertainties with that judgment remain

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

### 3.2.2 Pulmonary Function

This section describes research on formaldehyde inhalation and pulmonary function effects in experimental and observational studies in humans. The study selection criteria (PECO) included studies of pulmonary function responses to any exposure duration including long term occupational or continuous residential exposure, episodic exposures during anatomy classes, or controlled human exposure studies for a few hours. EPA focused the hazard evaluation on exposure settings most relevant to the dose-response assessment and derivation of a RfC for chronic duration exposure scenarios. These studies include occupational studies of workers with long-term exposure (typically, years), residential or school exposures to adults or children, and episodic (weekly) exposures to medical students in anatomy classes followed over a period of months. Studies of acute- and short-term exposure scenarios did not provide a clear indication of effects on pulmonary function and these results are summarized in the appendix (see Appendix C.5.1 for controlled human exposure studies and Appendix C.5.2 for studies of workers or medical students and pulmonary function changes across a work shift or over a dissection lab). Animal studies of analogous endpoints were not included in the hazard evaluation because there were few directly relevant studies in the peer-reviewed literature and the extensive literature on these endpoints in humans was considered adequate to draw a hazard conclusion.

The review of the epidemiological literature provides evidence that long-term formaldehyde exposure is associated with declines in pulmonary function, including forced expiratory volume (FEV_1_), forced vital capacity (FVC), FEV_1_/FVC, and expiratory flow rates. Pre-shift pulmonary function was lower in highly exposed occupational groups employed at exposed jobs for long durations compared to their nonexposed or lesser-exposed comparison groups. The few longitudinal studies found evidence of declines in some measures in excess of that expected from aging, although the duration of follow-up and individual variation combined with small group sizes may have resulted in lack of associations with other measures. Panel studies of anatomy students also provide evidence that formaldehyde exposure during dissections results in declining pulmonary function over time. There are few studies of residential exposure; however, a clear exposure-response relationship in children was reported by a well-conducted residential study with most household concentrations <0.045 mg/m^3^ (Krzyzanowski et al., 1990). There is mechanistic support, primarily from studies in animals, for the biological plausibility of formaldehyde exposure-induced effects on decreased pulmonary function, although a definitive MOA(s) has not been fully defined. Overall, the most relevant mechanistic evidence (predominantly evidence interpreted as moderate or robust) included inflammatory structural alterations and eosinophil increases in the lower airways that appear to be at least partially related to indirect activation of sensory nerve endings. However, the initial cellular or tissue modifications that ultimately lead to these later events are not understood, and given the limitations of the available studies, it is unclear whether and to what extent certain events would be triggered with chronic, low-level exposure. Although there is an expectation that other important mechanistic events would be identified with additional study, the available data were interpreted to provide reasonable support for the biological plausibility of the observed associations and to identify what is likely to be an incomplete mechanism by which formaldehyde inhalation could cause decreased pulmonary function.

Spirometric measures are used along with other diagnostic criteria in the evaluation of asthma and chronic obstructive pulmonary disease in individuals. While a group mean decrement in any pulmonary function measure does not indicate that the prevalence of these respiratory diseases has increased, EPA considered a decrease in mean values to suggest a shift toward a decline in the respiratory health status of the population. Poor pulmonary function, as well as a decrease in pulmonary function, is an important health endpoint associated with the development of chronic respiratory disease, coronary heart disease, and mortality (Young et al., 2007; Sorlie et al., 1989; Sin et al., 2005; Schunemann et al., 2000; Schroeder et al., 2003; Menezes et al., 2014; Clayton et al., 2014). The American Thoracic Society evaluated the clinical significance of small average declines in pulmonary function observed in a population in response to air pollutants and concluded that although the magnitude of the observed declines may not be clinically relevant to an individual, a shift in the population distribution toward lower pulmonary function, assuming the association is causal, may have a large impact on public health (ATS, 2000).

Overall, based on moderate human evidence from observational epidemiology studies, with corresponding slight evidence for an effect in animals based on mechanistic studies supporting biological plausibility, the evidence indicates that long-term inhalation of formaldehyde likely causes decreased pulmonary function in humans given sufficient exposure conditions. The primary support for this conclusion includes a study of children and adults in a residential setting (mean, 0.03 mg/m^3^, maximum 0.17 mg/m^3^) and numerous studies of workers with long-term exposure to >0.2 mg/m^3^.

#### Human Studies

The synthesis of pulmonary function first discusses studies of long-term exposures among occupational groups or residential populations of adults and children. Then, panel studies of students in anatomy labs with episodic exposure over a period of weeks or months are discussed. Evidence tables for each exposure setting (see Tables 3-5 through 3-8) are organized by level of confidence in the study’s results and then descending publication year. The table summarizing the studies of occupational exposure are organized first by study design (cross-sectional, longitudinal), then by confidence in study results and descending publication year. Eleven of the studies that met the PECO criteria were considered not informative after evaluation (Tanveer et al., 1995; Sripaiboonkij et al., 2009; Pourmahabadian et al., 2006; Ostojić et al., 2006; Mohammad `pour and Maleki, 2011; Milton et al., 1996; Marks et al., 2010; Kilburn et al., 1985; Kilburn et al., 1989a; Imbus and Tochilin, 1988; Gamble et al., 1976). The study evaluations are included in Appendix B.3.3. Generally, in the included studies of formaldehyde exposure and effects on pulmonary function, groups exposed to formaldehyde during the course of their jobs experienced TWA concentrations above 0.2 mg/m^3^ with intermittent peaks above 1 mg/m^3^ (see Table 3-5). Students meeting once or twice a week in anatomy labs experienced fluctuating concentrations during dissections averaging between 0.1 and >1.0 mg/m^3^ (see Table 3-8). Formaldehyde concentrations in residential or primary school settings were much lower, continuous, and less variable (<0.1 mg/m^3^) (see Tables 3-6 and 3-7).

##### Occupational exposure

Overall, the set of occupational studies indicates that inhalation of formaldehyde over long periods at work is associated with deficits in measures of pulmonary function. With only a few exceptions, average values for FEV_1_, FVC, and FEF measured before a work shift at the beginning of the work week were lower among exposed workers than average values in their referent groups (see Table 3-5). The occupational groups under study were exposed to high average formaldehyde concentrations (≥0.2 mg/m^3^) in a variety of industries, including funeral homes (embalming), wood products (plywood, cabinetry), chemical products (formaldehyde resins), and manufacturing. Employees had worked at these jobs for at least 5 years, and in a few studies, for more than 10 years. While a few studies conducted longitudinal analyses (Nunn et al., 1990; Löfstedt et al., 2011; Alexandersson and Hedenstierna, 1989), most of the occupational studies were cross-sectional in design, recruiting only current employees (Schoenberg and Mitchell, 1975; Neghab et al., 2011; Malaka and Kodama, 1990; Löfstedt et al., 2009; Levine et al., 1984b; Khamgaonkar and Fulare, 1991; Horvath et al., 1988; Holmström and Wilhelmsson, 1988; Herbert et al., 1994; Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988). In general, when only current employees are recruited for a cross-sectional study of an exposure that causes symptoms, there is a possibility that former workers may have left their jobs to reduce their exposure (lead time bias, healthy worker survival effect). Further, for studies that recruited from among those present on the day of the study, if employees were not present because of symptoms related to their formaldehyde exposure, attenuated effect estimates may have been observed (Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988). Additional limitations also were identified that could result in attenuated risk estimates, which are noted in the evidence summary table (see Table 3-5). Despite their decreased sensitivity, most studies observed deficits in pre-shift pulmonary function associated with formaldehyde exposure, which increased EPA’s confidence in their findings. Moreover, an increase in pulmonary function deficits with increasing cumulative exposure was reported in a study of woodworkers with area formaldehyde levels ranging from 0.27−4.28 mg/m^3^ (Malaka and Kodama, 1990).

Figure 3-5 presents forest plots of the difference in mean FEV_1_, FVC, and FEF_25-75_ between exposed and referent groups for 10 study results reported by 9 publications. Mean FEV_1_ in exposed groups was consistently lower than their un- or lesser-exposed referent group across all industries, ranging from −3.6 to −9.5 percent in wood products workers, −1.7 to −12.2 percent in chemical manufacture workers, and −1.5 percent in embalmers. While no difference in mean FVC (%) was found by a few of the studies, and a higher mean was reported by a small study, most of the comparisons indicate that exposed groups had lower mean values compared to their respective referent group ranging from −2.0 to −8.1 percent in wood products workers and −6.6 to −13.9 percent in chemical manufacture workers. A set of four studies of wood products workers reported consistently lower mean FEF_25-75_ compared to their unexposed referent groups ranging from −2.0 to −10.4 percent. Studies that reported only the absolute values or used a different analysis could not be plotted (Levine et al., 1984b; Khamgaonkar and Fulare, 1991; Herbert et al., 1994). All reported deficits in pulmonary function measures among exposed groups with varying degrees of precision.

In general, the studies of formaldehyde exposure in wood products industries reported the highest average and peak concentrations (TWA 0.4–1.0 mg/m^3^, maximum 1.3–4.3 mg/m^3^) (Malaka and Kodama, 1990; Horvath et al., 1988; Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988), although levels were reported to be lower in two studies (minimum, 0.1 and 0.05 mg/m^3^; maximum, 0.3 and 0.5 mg/m^3^) (Holmström and Wilhelmsson, 1988; Herbert et al., 1994). Average concentrations in the chemical industries generally were lower and less variable, although there was variation between industries. Average concentrations in a melamine resin factory were 1.0 ± 0.49 mg/m^3^ (Neghab et al., 2011) in contrast with 0.1 mg/m^3^ (range 0.01–0.4 mg/m^3^) among Hot Box foundry workers (Neghab et al., 2011). Differences in exposure levels between studies of these highly and variably exposed occupational groups do not clearly explain differences in the magnitude of deficits observed among exposed groups compared to their referent.

Figure 3-5 Forest plots depicting mean difference in pre-shift pulmonary function (percentage predicted) between exposed and comparison groups for FEV_1_, FVC, and FEF

The plots show the author and year, number of exposed (HCHO) and unexposed referents (Ref), and the mean difference in preshift values (%) between exposed and referents. The plots include results from six studies that reported the percentage of predicted normal function accounting for age, gender, and height, and three studies that reported mean absolute values and mean reference values for exposed and referent groups from which the percentage of the reference group could be calculated (Holmström and Wilhelmsson, 1988; Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988). The forest plot compares the mean difference between all exposed and referent groups when available, although one study reported appropriate data only for subgroups [e.g., low, and high exposure categories; (Malaka and Kodama, 1990)]. The average of the standard deviations for a spirometric parameter specific to an exposure group, weighted by the size of the referent group, was used when no statistics from the individual study were available (Holmström and Wilhelmsson, 1988; Alexandersson et al., 1982; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988).

In addition to accounting for age, gender, and height, most of the studies adjusted for smoking in their statistical analyses or otherwise addressed potential confounding by smoking. (Nunn et al., 1990; Neghab et al., 2011; Malaka and Kodama, 1990; Löfstedt et al., 2011; Levine et al., 1984b; Horvath et al., 1988; Holness and Nethercott, 1989; Holmström and Wilhelmsson, 1988; Herbert et al., 1994; Alexandersson and Hedenstierna, 1989).

The studies evaluated three types of occupational settings—wood products industries, chemical production, and mortuaries—and employees in these industries were exposed to other chemical and physical agents that may co-occur with formaldehyde. Other common exposures in the wood products industry can include phenols and other solvents contained in resins and glues, terpenes, and dust, while embalming fluids include methanol. Phenol and terpenes are not expected to have strong effects on pulmonary function, particularly at the concentrations reported by the studies. However, occupational exposure to high concentrations of wood dust (>2 mg/m^3^) has been associated with reductions in pulmonary function (Mandryk et al., 2000). Many of the studies of wood products workers reported measurements for dust, terpenes, and phenols, stating that levels were a fraction of occupational exposure limits. Studies that either adjusted for dust levels or compared effects in formaldehyde-exposed groups with and without dust exposure did not find an independent effect by dust (Malaka and Kodama, 1990; Holmström and Wilhelmsson, 1988). The chemical industries included manufacture of formaldehyde products such as formaldehyde-phenol or formaldehyde-melamine resins and may involve exposures to phenols, other alcohols, VOCs, and other compounds, some of which may affect pulmonary function. However, since a pattern of reduction in pulmonary function was observed across several different exposure settings, all involving high formaldehyde exposure (TWA concentrations above 0.2 mg/m^3^ with intermittent peaks above 1 mg/m^3^), confounding by a coexposure becomes less likely to be an alternative explanation for the observed associations.

Three studies conducted longitudinal analyses of small groups of workers with continued exposure over 4–6 years (Nunn et al., 1990; Löfstedt et al., 2011; Alexandersson and Hedenstierna, 1989). All three longitudinal studies measured FEV1 and reported no change in the cohorts over the study period. However, Nunn et al (1990), a study of workers at a formaldehyde-urea resin manufacturing factory reported that among exposed nonsmokers, the annual decline was −45 mL/year (95% CI −28, −62 mL/year), which is 50% greater than the expected rate of age-related decline in FEV1 in nonsmokers (−29 mL/year), (Redlich et al., 2014; Lee and Fry, 2010). The annual decline among unexposed nonsmokers in this study was −29 mL/year, consistent with the expected rate of decline with age. In addition, Alexandersson and Hedenstierna (1989) reported a decline in FEF25−75 at a TWA concentration of 0.42−0.5 mg/m3. FEF25−75 percentage among the carpentry workers declined by −168 ± 46 mL/second (10.1 L/minute) for each year of exposure over a 5-year period (p < 0.001). There was a larger decrease among nonsmokers compared to smokers (−212 mL/sec/year and −60 mL/sec/year, respectively). The annual decrease was corrected for aging and reference pulmonary function spirometry values. The number of years that participants were followed by the three studies, 4–6 years, is the minimum length of time considered adequate to observe changes (Redlich et al., 2014). Given the large amount of within-person variability in these measures when assessed over time, these studies would have had limited sensitivity to detect a small longitudinal change. Further, information in the reports for the three studies indicated a potential differential loss to follow-up of exposed individuals who may have changed jobs or left the industry because of the irritation effect of formaldehyde. Despite the low sensitivity of these studies, declines in FEV1 and FEF25−75 over time were reported.

Duration of work in an exposed job was associated with decreased pulmonary function values in two studies (Schoenberg and Mitchell, 1975; Neghab et al., 2011), but not others (Horvath et al., 1988; Holmström and Wilhelmsson, 1988; Alexandersson et al., 1982). These analyses controlled for age, height, gender, and cigarette smoking. One study examined associations with cumulative exposure (ppm-years) and observed reductions in pulmonary function measures (FEV_1_, FEV_1_/FVC, and FEF_25−75_) among male employees at a plywood company who had worked an average of 6–7 years (Malaka and Kodama, 1990). In addition to other relevant covariates, this analysis controlled for cigarette smoking and dust levels in the regression model. Another study among wood products employees reported no association with a cumulative exposure measure, but did not present the results quantitatively (Holmström and Wilhelmsson, 1988).

Table 3-5 Formaldehyde effects on pulmonary function in occupational settings

Study and design | | | Results
Cross-sectional studies
Reference: Horvath et al. (1988); Cross-sectional study, Wisconsin.; Population: 109 exposed (workers at a particleboard and molded products operation, 68.6% of all exposed), average age 37.4 ± 11.7 years, 57% males; 53.2% current and former smokers, average work duration in exposed: 10.3 years (1−20 years). 254 unexposed (workers from nearby food processing facilities; average age 34.2 ± 10.6 years, 44% male). 53.1% current and former smokers.; Exposure: 8-hour TWA measured using personal passive monitors on the day of the exam (LOD 0.15 mg/m^3^). Area levels measured with an active sampling train (impingers).; TWA 0.69 ppm, range 0.17−2.93 ppm (0.85 mg/m^3^, range 0.21−3.60 mg/m^3^),^a^ and 0.05 ppm, range 0.03−0.12 ppm (0.062 mg/m^3^, range 0.037−0.15 mg/m^3^)^b^ in the exposed and unexposed industries, respectively.; Other exposures in exposed: Respirable particulates (PEL 5 mg/m^3^): median 0.11 mg/m^3^; phenol (PEL 5 ppm): mean 0.15 ppm; carbon monoxide (PEL 50 ppm): mean 7.35 ppm; sodium hydroxide (PEL 2 mg/m^3^): 0.4−0.21 mg/m^3^; nitrogen dioxide: ND; acrolein: ND.; Methods: Spirometry (volumetric) before and after the work shift. Pulmonary function (ATS methods) as percentage of predicted normal compared between exposed and unexposed (unpaired t-test); multiple linear regression of baseline absolute values by exposure group, adjusting for age, height, sex, and smoking.; Evaluation: ^a^; High confidence | | | Comparison of mean preshift pulmonary function (percentage predicted (SD))
| | | | Exposed | | Referent
| | | FEV_1_ (L) | 103 (13) | | 105 (13)
| | | FVC (L) | 105 (12) | | 107 (13)
| | | FEV_1_/FVC | 96 (8) | | 95 (8)
| | | PEFR (L/sec) | 100 (23) | | 103 (22)
| | | FEF_25−75_ (L/sec) | 83 (22) | | 85 (25)
| | | FEF_25_ (L/sec) | 6.91 (2.12) | | 6.73 (1.98)
| | | FEF_50_ (L/sec) | 4.5 (1.46) | | 4.38 (1.43)
| | | FEF_75_ (L/sec) | 1.63 (0.8) | | 1.66 (0.77)
| | | p > 0.05
| | | Exposure group was not associated with baseline absolute values in multiple linear regression models. Work duration was not associated with preshift pulmonary function.
| | | FEV_1_, forced expiratory volume in 1second; FVC, forced vital capacity; PEFR, peak expiratory flow rate; FEF, forced expiratory flow; FEF_25, 50, 75_ indicate flow expiratory flow rates at 25%, 50%, and 75% of FVC, respectively.
Reference: Neghab et al. (2011); Cross-sectional study, Iran.; Population: 70 male workers at a local melamine-formaldehyde resin-producing factory with current exposure to formaldehyde and ≥2 years work history (mean age 38.2 ± 8.4 years, work duration 13.2 ± 7.8 years, 24.3% smokers).; 24 healthy males from the same industry and comparable socioeconomic and demographic status, and no present or former formaldehyde or other exposure to respiratory irritants. 100% participation (mean age 40.0 ± 8.2 years, work duration 14.5 ± 8.1 years, 25% smokers).; Exposure: Area samples (N = 7) in seven workshops with exposure and one area sample in office area (sampling in different time points and shifts). Sampling time 40 minutes. Exposed mean formaldehyde: 0.78 ± 0.4 ppm (0.96 ± 0.49 mg/m^3^)^b^; referent: not detected.; Methods: Pulmonary function tests (Vitalograph COMPACT), ATS methods) before and at the end of the work shift on the first working day of week, percentage predicted.; Group comparisons and cross-shift difference among exposed, and multiple linear regression analysis of pulmonary function comparing exposed and referent adjusting for smoking, age, weight, height.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. | | | Percentage predicted pulmonary function (mean (SD))
| | | | Exposed Preshift (N = 70) | | Referent (N = 24)
| | | VC | 77.9 (12.0)^a^ | | 99.3 (21.0)
| | | FVC | 86.6 (14.5)^a^ | | 100.5 (14.5)
| | | FEV_1_ | 86.6 (14.4)^a^ | | 98.8 (14.6)
| | | FEV_1_/FVC | 100.2 (8.8) | | 98.8 (5.3)
| | | PEF | 90.9 (15.9) | | 89.8 (31.2)
| | | ^a^Difference between exposed and referent, p < 0.025
| | | Difference in pulmonary function between exposure groups; Regression coefficients (percentage difference; SD provided by author; p-value):; VC −21.43 (3.48) (p = 0.001); FVC −13.88 (3.44) (p = 0.001); FEV_1_ −12.23 (3.42) (p = 0.001); Change in pulmonary function per year work duration; Regression coefficients (unit change/year):; VC −0.1 (p = 0.315); FVC −0.43 (p = 0.02); FEV_1_ −0.375 (p = 0.035); FEV_1_/FVC −0.1 (p = 0.225); PEF −0.28 (p = 0.2); VC, vital capacity; FVC, forced vital capacity; FEV_1_, forced expiratory volume in the first second; PEF, peak expiratory flow.
Reference: (Herbert et al., 1994); Cross-sectional study, Canada.; Population: 99 oriented strand board workers (exposed, 98% participation), mean age 35.4 years, 51.5% smokers; work duration 5.1 years; 165 oil/gas field plant workers (not exposed to formaldehyde or oil and gas vapors) from same geographic area (82% participation), mean age 34.9 years, 27.9% smokers, work duration 10 years. Excluded 14 workers in referent with hydrogen sulfide exposure.; Exposure: TWA formaldehyde and dust concentrations at OSB plant based on 21 hours of continuous sampling in the breathing zone at five work sites on 2 separate days.; Formaldehyde range: 0.07−0.27 ppm (0.09−0.33 mg/m^3^),^b^ dust mean: 0.27 mg/m^3^, 2.5 μm diameter.; Methods: Spirometric testing (volumetric, best of five satisfactory maneuvers) at start of work shift and after 6 hours (ATS guidelines).; Analysis ANCOVA controlling for age, height, and smoking.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. Possible irritant exposure in referent. | | | Preshift pulmonary function (mean) by exposure group
| | | | OSB | | Oilfield
| | | FEV_1_ (mL) | 4.203 | | 4.223
| | | FVC (mL) | 5.364 | | 5.257
| | | FEV_1_/FVC (%) | 78.6^a^ | | 80.3^a^
| | | ^a^p = 0.028
| | | Risk of airway obstruction (FEV_1_/FVC < 75%) by smoking category (N = number below criteria)
| | | | Odds Ratio | | 95% CI
| | | Nonsmokers (17) | 1.68 | | 0.54, 5.25
| | | Exsmokers (15) | 1.08 | | 0.32, 3.64
| | | Current (25) | 2.98 | | 1.10, 8.07
Reference: Khamgaonkar and Fulare (1991); Cross-sectional study, India.; Population: 74 individuals working in anatomy and histopathology departments at three colleges and exposed to formaldehyde. Selected every 2nd person from occupational list. Comparison group matched by age and sex (N = 74) (individuals not working in laboratories with formaldehyde). Comparable for mean height and weight. Excluded persons with a history of pulmonary disease before their present occupation.; Exposure: Multiple 30-minute area samples collected in the breathing zone in both the exposed (N = 43) and unexposed (N = 18) areas.; Mean (SD) exposed 1.00 ppm (0.556), range 0.036−2.27 ppm (1.23 mg/m^3^ (0.68), range 0.044−2.79 mg/m^3^).^b^; Referent 0.102 ppm (0.115), range 0−0.52 ppm (0.125 mg/m^3^ (0.141) range ND−0.64 mg/m^3^).^b^; Methods: Pulmonary function tests on a subset of 37 exposed and 37 comparison individuals on a Monday morning after days of no exposure.; Evaluation: ^a^; Medium confidence (↓); Possible exposures in referent that affect pulmonary function; exposure to formaldehyde in referent labs. | | | Mean pulmonary function values by exposure group
| | | | Exposed (N = 37) | | Referent (N = 37)
| | | FVC (L) | 2.18 | | 2.63^a^
| | | MMEFR (L/sec) | 1.55 | | 2.71^b^
| | | FEV_1_ (%) | 60.68 | | 78.74^a^
| | | ^a^p < 0.01, ^b^p < 0.05
| | | FVC, forced vital capacity; MMEFR, maximum mid-expiratory flow rate; FEV_1_, forced expiratory volume in 1 second.
Reference: Malaka and Kodama (1990); Cross-sectional study, Indonesia.; Population: Male employees at plywood company. Exposed workers (N = 93) randomly selected with stratification by smoking status and work duration (<5 and ≥5 years; 93% participation), mean age 26.6 years, work duration 6.2 ± 2.4 years; unexposed group (N = 93) matched for age, ethnicity, and smoking status (53%), mean age 28.8 years, similar in height, work duration 6.7 ± 2.3 years, worked in areas where formaldehyde was not used, and had no previous or current exposure to formaldehyde based on occupational histories; 93% participation rate.; Exposure: Area sampling and personal monitoring. Average exposed 0.9 ppm (1.1 mg/m^3^),^b^ range 0.22−3.48 ppm (0.27−4.28 mg/m^3^)^b^; calculated by EPA from weighted average of area specific averages in Table 2 in the paper; referent 0.003−0.07 ppm (0.0037−0.09 mg/m^3^).^b^; Cumulative exposure measure developed using area concentrations and duration in current job (mean 6.29 ppm-year, SD 2.72). Categorized into none (N = 93), low (<5 ppm-year) (N = 37), and high (≥5 ppm-year) (N = 56).; Other exposures: average total dust 1.35 mg/m^3^, average respirable dust 0.6 mg/m^3^.; Methods: Baseline (Monday) and cross-shift spirometric measurements (volumetric) followed ATS methods.; Pulmonary function (percentage of expected function) by category of cumulative exposure analyzed using analysis of covariance. Stepwise regression of pulmonary function on cumulative formaldehyde (continuous) adjusted for age, height, weight, cigarettes/day, and dust.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. | | | Mean baseline spirometric values (adjusted for dust) (SD)
| | | | Exposed | | Referent
| | | FEV_1_/FVC (%) | 84.7 (6.5) | | 86.9 (4.9)^a^
| | | FEV_1_ (L) | 2.78 (0.41) | | 2.82 (0.30)^a^
| | | FVC (L) | 3.28 (0.44) | | 3.37 (0.36)
| | | FEF_25−75%_ (L/sec) | 3.04 (0.76) | | 3.44 (0.78)^a^
| | | ^a^p < 0.005
| | | Multiple regression model of pulmonary function^a^
| | | | β(per ppm-year FA)
| | | FEV_1_/FVC (%) | −0.347^b^
| | | FEV_1_ (L) | −0.015^b^
| | | FVC (L) | NS
| | | FEF_25−75_ (L/sec) | −0.043^b^
| | | ^a^adjusted for age, height, weight, cigarettes/day, and dust.; ^b^p < 0.05
| | | Mean pulmonary function (percentage predicted) (SD) by Categories of Cumulative Exposure
| | | | None | Low | High
| | | FEV_1_ | 94.4 (20.0) | 87.4 (10.2) | 90.8 (12.7)
| | | FVC | 92.0 (9.2) | 87.1 (8.4) | 91.7 (10.4)
| | | FEV_1_/FVC | 86.9 (4.9) | 85.3 (6.4) | 84.4 (6.5)
| | | FEF_25−75_ | 90.4 (20.0) | 79.5 (18.2) | 80.0 (20.1)
| | | Dust was not associated with any pulmonary function measures.
Reference: Holness and Nethercott (1989); Cross-sectional study of funeral workers, Canada.; Population: 67 currently active embalmers and 17 formerly active, recruited through a list of funeral homes from a district funeral directors association (86.6% participation). Average work duration 10 years. Unexposed group (N = 38) recruited from large service organization and paid student volunteers.; Exposure: Average concentration from two area samples (impingers), measured during embalming procedures lasting from 30 to 180 minutes, 0.36 ± 0.19 ppm, range 0.08−0.81 ppm (0.44 ± 0.23 mg/m^3^, range 0.10−1.0 mg/m^3^).^b^; Unexposed average concentration: 0.02 ppm (0.025 mg/m^3^).^b^; Methods: Information on symptoms, past and family medical history, and work practices by questionnaire.; Spirometry (volumetric) tests on 22 embalmers before and after embalming procedure and on 13 referents 2−3 hours after first test.; Pulmonary function (percentage predicted) compared using multiple regression, correcting for age, height, and pack-years smoked.; Evaluation: ^a^; Medium confidence; Differences in source populations for exposed and referent groups lead to uncertainty in comparability, with no consideration of potential confounding. | | | Comparisons of baseline pulmonary function (percentage predicted) (SD)
| | | | Exposed (N = 84) | | Unexposed (N = 38)
| | | FVC | 100.5 (12.3) | | 100.9 (11.5)
| | | FEV_1_ | 99.2 (12.9) | | 100.7 (12.9)
| | | FEV_1_/FVC | 98.4 (7.9) | | 99.4 (8.7)
| | | FEF_50_ | 104.8 (29.7) | | 110.3 (34.5)
| | | FEF_75_ | 76.2 (32.9) | | 86.6 (36.0)
| | | | Active (N = 67) | | Inactive (N = 17)
| | | FVC | 100.7 (12.2) | | 95.8 (12.0)^a^
| | | FEV_1_ | 100.8 (12.19) | | 93.1 (14.1)^b^
| | | FEV_1_/FVC | 98.9 (7.8) | | 96.6 (8.0)
| | | FEF_50_ | 107.5 (28.7) | | 94.1 (32.3)
| | | FEF_75_ | 80.8 (33.1) | | 57.1 (24.7)
| | | ^a^p = 0.0385, ^b^p = 0.0652
Reference: Alexandersson and Hedenstierna (1988); Alexandersson (1988); Cross-sectional study, carpentry shop, Sweden.; Population: 38 exposed employees working with acid-hardening lacquers for the previous 12 months [mean age (SD): 34 (10) years, mean duration employment 7.8 years] and at work on the study day. 18 referent employees at the same company (mean age [SD] 37 [9] years). Asthmatics excluded.; Exposure: Personal exposure monitored during three to four 15-minute periods during the workday. No formaldehyde measurements reported for referent group.; TWA 0.40 mg/m^3^, range: 0.12−1.32 mg/m^3^. Peak concentration (15 minute) 0.70 mg/m^3^, range 0.14−2.6 mg/m^3^.; Additional measurements of solvents and dust (4 hr)—considered very low compared to Swedish threshold limit values.; Methods: Spirometry (volumetric) on Monday after 2 days unexposed and again at end of shift on second day. Half of referent employees tested before, and half tested after, shift. Compared difference from sex, age, and height matched reference values.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. Small sample size in referent. | | | Pulmonary function before work on Monday (Mean difference from reference values)
| | | | Exposed (N = 38) | | Referent (N = 18)
| | | | Difference (SD) | | Difference (SD)
| | | FVC (L) | −0.24 (0.64)* | | 0.03 (0.65)
| | | FEV_1_ (L) | −0.21 (0.51)** | | 0.15 (0.42)
| | | FEV% | −0.7 (6.7) | | 1.8 (5.3)
| | | FEV_25−75_ (L/sec) | −0.10 (0.98) | | 0.31 (0.76)
| | | *p < 0.05; **p < 0.01
| | | Difference from reference values greater among nonsmokers than smokers.
Reference: Holmström and Wilhelmsson (1988); Cross-sectional study, Sweden.; Population: 3 study groups: 70 individuals (87% male) in formaldehyde products group (mean age 36.9 years); 100 furniture workers exposed to formaldehyde and wood dust (93% males, mean age 40.5 years). Comparison group, 36 persons (56% male, mean age 39.9 years), primarily local government clerks. 100% participation. Mean duration of employment 10.4 years for exposed and 11.4 years for referent group.; Exposure: Mean formaldehyde in 1985.; Group 1: mean 0.26 ± 0.17 mg/m^3^, range 0.05−0.5 mg/m^3^, Dust ≤1 mg/m^3^.; Group 2: mean 0.25 ± 0.05 mg/m^3^, range 0.2−0.3 mg/m^3^, dust 1.65 ± 1.06 mg/m^3^.; Referent: mean 0.09 mg/m^3^.; Data on formaldehyde concentrations available 1979−1984 and from 1 to 2 hours personal sampling in breathing zone at different workstations in 1985.; Mean annual exposure estimated for each participant from start of employment; dose-years.; Other exposures (phenol, ammonia, epichlorhydrin, methanol, ethanol) <1% of occupational exposure limit.; Methods: Spirometric measures analyzed as percentage of expected normal based on age, sex, smoking, height, and weight.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. Comparison groups selected from different source populations. | | | Pulmonary function values compared to expected by exposure group
| | | | FA exposed (N = 70) | FA-dust exposed (N = 98) | Referent (N = 36)
| | | FVC
| | | Observed | 4.979^a^ | 4.929^a^ | 4.539
| | | Expected | 5.556 | 5.593 | 4.718
| | | FEV%
| | | Observed | 80.8 | 78.3 | 81.4
| | | Expected | 80.6 | 79.5 | 80.7
| | | ^a^paired t-test comparing observed to expected, p < 0.001.
| | | No correlation of FVC with cumulative formaldehyde dose or years of service >5 years.
Reference: Levine et al. (1984b); Cross-sectional study, USA, 1978.; Population: 105 white, male morticians attending postgraduate course (94% participation).; Exposure: # embalmings.; Exposure index: rank ordering of the total # embalmings; divided into categories of low and high exposure based on # bodies embalmed, matched on age (within 3 years).; Methods: Completed self-reported respiratory disease questionnaire (ATS) and detailed occupational history; pulmonary function testing (volumetric spirometer) (N = 99), analysis of 90 with complete data after excluding pipe and cigar smokers.; Evaluation: ^a^; Medium confidence; Uncertainty regarding assignment of exposure rank. | | | Change in pulmonary function per unit exposure rank (N = 90)
| | | Variable | | Exposure Rank
| | | FVC (L) | | +0.0003
| | | FEV_1_ (L) | | −0.0001
| | | FEV_1_/FVC | | +0.0019
| | | FEF_25−75_ (L/s) | | −0.0016
| | | FEF_25−75_/FVC | | −0.0002
| | | Rank FVC/predicted | | −0.0547
| | | Rank FEV_1_/predicted | | +0.0229
| | | FEF_25−75_/predicted | | −0.0676
| | | Coefficients were not statistically significant (p > 0.05).; Multiple regression equations adjusted for age, height, number of pack-years, and exposure index.
| | | Comparison of pulmonary function by exposure group (low, high) in nonsmokers (N = 24); mean (SE)
| | | Measure | Low | | High
| | | FVC (L) | 4.69 (0.22) | | 4.56 (0.32)
| | | FVC % predicted | 100.5 (3.1) | | 98.9 (3.4)
| | | FEV_1_ (L) | 3.80 (0.22) | | 3.64 (0.27)
| | | FEV_1_ % predicted | 108.9 (3.3) | | 105.5 (4.1)
| | | FEV_1_/FVC | 0.807 (0.02) | | 0.797 (0.02)
| | | FEF_25−75_ (L/sec) | 4.28 (0.48) | | 3.88 (0.49)
| | | FEF_25−75_ % predicted | 117.9 (8.8) | | 110.5 (11.7)
| | | Groups matched on age, similar in height Group comparisons, p > 0.05
Reference: Alexandersson et al. (1982); Cross-sectional study, Sweden.; Population: 47 exposed carpentry workers employed at the plant for >1 year and at work on study day (mean age 35 years, mean duration 5.9 years) and 20 unexposed employees. No asthmatics were included.; Exposure: TWA concentration, measured using personal sampling over a working day, 0.47 mg/m^3^ (range 0.05−1.62 mg/m^3^).; Other exposures: Terpenes: range ND−9 mg/m^3^; dust (all particle sizes) mean 0.5 mg/m^3^ (range 0.3−0.7 mg/m^3^).; Methods: Spirometric measurements (volumetric, ATS methods) Monday morning preshift and after work for exposed. Pulmonary function was measured in the unexposed in the morning or the afternoon. Statistical analysis of preshift values and cross-shift change, two-tailed Student’s t-test. Linear regression of association with duration of employment.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. P-values were reported. | | | Comparisons of pre-shift mean pulmonary function (SD)
| | | | Exposed (N = 47) | | Referent (N = 20)
| | | FVC (L) | 5.73 (0.14) | | 6.0 (0.2)
| | | FEV_1_ (L) | 4.52 (0.12)^a^ | | 4.86 (0.15)
| | | FEV% | 79.2 (1.0) | | 80.7 (1.32)
| | | MMF (L/sec) | 4.94 (0.2) | | 5.08 (0.31)
| | | CV% | 16.7 (1.07) | | 17.1 (1.5)
| | | ^a^Difference from reference value, p = 0.08
| | | No association with duration of employment (quantitative results not presented).
Reference: Schoenberg and Mitchell (1975); Cross-sectional study, USA.; Population: Employees using formaldehyde-phenol resin in the filter acrylic wool filter department of a filter manufacturing plant.; Exposed production line workers and supervisors, N = 63 (94% of recruited); younger age and cigarette smoking (packs/year) less among present line group compared to never on-line.; Exposure: Measurements taken by insurance company during same month; 0.5−1 mg/m^3^.; 3 breathing zone samples, 10.6−16.3 mg/m^3^.; Exposure groups; Present line, N = 40; Previous line, N = 8; Never-on-line, N = 15; Some in never-on-line had some exposure.; Other exposures:; Phenol, four breathing zone samples, 7−10 mg/m^3^.; Methods: Standardized questionnaire, pulmonary function measured before and after shift on Monday and Friday (pneumotachometer); 5 maneuvers, average of best two used to calculate values; compared to predicted based on age, height, and gender.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association. Multiple exposures: formaldehyde, phenol. Phenol is an irritant but may not be associated with pulmonary function at these levels. Small sample size. | | | Monday preshift pulmonary function by exposure duration (mean, SEM)
| | | | Never (N = 15) | <1 year (N = 15) | 1–4 years (N = 10) | >5 years (N = 15)
| | | FVC^a^ | 104.3 (2.9) | 103.7 (2.9) | 108.8 (2.7) | 112.2 (3.8)
| | | FEV_1_^a^ | 98.9 (3.6) | 100.7 (3.1) | 99.6 (3.5) | 97.2 (4.4)
| | | FEV_1_/FV C, %^b^ | 79.4 (1.3) | 79.9 (1.4) | 74.1 (2.2) | 71.2 (2.6)^c^
| | | MEF_50%_/FVC, %^b^ | 90.3 (4.0) | 87.1 (6.1) | 73.6 (8.4) | 64.0 (6.2)^d^
| | | ^a^Percentage predicted; ^b^Standardized to cigarette consumption of 15 pack-years; ^c^Different from never-on-line group (p < 0.05); ^d^Different from never-on-line group (p < 0.005)
Reference: Main and Hogan (1983); Cross-sectional study, USA.; Population: 21 exposed individuals working in two mobile trailers for 34 months (mean age 38 ± 9 years, 76% male, 19% nonsmokers).; 18 referent individuals who did not work in the trailers (mean age 30 ± 6 years, 50% male, 22% nonsmokers).; Exposure: Three 1-hour area samples using impingers taken on four occasions (August, September, December, April) always on a Monday. At least one sample from each office in both trailers. Concentration range 0.12 to 1.6 ppm (0.15−1.97 mg/m^3^).^b^; Methods: Volumetric spirometer, percentage predicted FEV_1_ and FVC stratified by smoking status (unadjusted group means compared using t-tests).; Evaluation: ^a^; Low confidence; Comparison groups selected from different sources (possible unmeasured confounding), ETS in referent; small sample size (low sensitivity). | | | Mean pulmonary function (percentage predicted)
| | | | Exposed (N = 14) | | Unexposed (N = 17)
| | | FEV_1_ | 98 | | 99
| | | FVC | 94 | | 97
| | | FEF_50_ | 93 | | 90
| | | FEF_75_ | 69 | | 70
| | | %Δ FEF_50_ | 55 | | 43
Longitudinal studies
Reference: Nunn et al. (1990); Prospective study at chemical factory manufacturing urea formaldehyde resin, Duxford, England.; Population: Exposed: 164 workers, aged 25 or older, exposed to free formaldehyde in 1980; 29% <35 years, 46% current smokers, 22% employed >22 years; referent: 129 workers from bonded structures division at same factory in 1980; 39% <35 years, 45% current smokers, 4% employed >22 years. Followed over 6 years (1980−1985).; Exposure: Area samples (1−6 hours) periodically, 1979 and 1985, and personal sampling for representative exposed workers, 1985 to 1987. Exposure prior to 1976 based on subjective determinations and knowledge of process changes and industrial hygiene measures. Pre-1979 levels estimated as low, medium, and high, corresponding to an 8-hour day.; TWA of 0.1−0.5 ppm (0.12−0.62 mg/m^3^),^b^ 0.6−2.0 ppm (0.74−2.46 mg/m^3^),^b^ and >2 ppm, respectively.; Other exposures: Records examined for random sample of 20 per group; more exposure to asbestos, carbon and glass fibers, siliceous fillers, aliphatic amines in referent group; both groups exposed to phenol and urea formaldehyde resin (not free formaldehyde).; Methods: Data on FEV_1_ and FVC (volumetric spirometer) highest of two readings within 5% of each other) obtained from routine annual health screenings conducted by the same nurse throughout the study period. Follow-up complete for 76% of exposed and 74% of unexposed. FEV_1_ values adjusted for height (FEV_1_/height^3^), regressed on time of screening visit for each worker, adjusted for age in 1980, smoking status in 1980, and at final assessment, maximum and mean exposure, assessment level, and total duration of exposure.; Evaluation: ^a^; Medium confidence (↓); Concern for selection bias: loss to follow-up higher among exposed with low pulmonary function compared to referent; referent exposed to other potential irritants. | | | Decline in FEV_1_ with age by smoking history (mean slope, mL/year (95% CI)
| | | Smoking status | Exposed | N | Unexposed | N
| | | Never | −45 (−28, −62) | 26 | −29 (−7, −51) | 13
| | | Exsmoker | −33 (−20, −46) | 34 | −40 (−26, −54) | 31
| | | Current | −46 (−33, −59) | 57 | −46 (−32, −61) | 36
| | | Total | −42 (−34, −51) | 117 | −41 (−32, −50) | 80
| | | Among those lost to follow-up, FEV_1_ was less than predicted among 75% of 12 exposed and 33% of 27 referent compared to 36% of 117 exposed and 45% of 80 referent followed.
Reference: Alexandersson and Hedenstierna (1989); Prospective occupational study, follow-up of Alexandersson et al. (1982), Sweden.; Population: 47 exposed cabinetry workers and 20 unexposed workers examined in 1980, 34 exposed and 18 unexposed were examined again in 1984. Of the 47 originally exposed, 13 had been reassigned to other unexposed jobs. Average exposure duration among exposed and transferred workers: 11 years.; Exposure: Personal monitoring during 3 or 4 15-minute periods during workday.; TWA 0.42 ± 0.27 mg/m^3^ in 1980 and 0.50 ± 0.12 mg/m^3^ in 1984.; Other exposures: terpenes ND; respirable dust: mean 0.1 ± 0.2 mg/m^3^.; Methods: Spirometric measures (volumetric, ATS methods) compared with reference values for sex, age, height, and weight. 5-year change corrected for age-dependent change. Results presented by smoking status.; Evaluation: ^a^; Medium confidence (↓); Potential for healthy survivor bias with attenuation in measure of association; small sample. | | | Annual change (1980−1984) in exposed, mean (SD)
| | | | Smokers (N = 10) | Nonsmokers (N = 11) | All (N = 21)
| | | FVC (mL/year) | −15 (24) | −10 (26) | −12 (16)
| | | FEV_1_ (mL/year) | −15 (21) | −31 (20) | −24 (20)
| | | FEV_1_/FVC (%/year) | −0.1 (0.4) | −0.4 (0.2)^a^ | −0.3 (0.3)
| | | FEF_25−75_ (mL/s/year) | −60 (69) | −212 (66)^a^ | −168 (46)^a^
| | | CV% (%/year) | −0.6 (0.3) | 0.2 (0.4) | −0.2 (0.3)
| | | ^a^p < 0.001, compared to predicted normal
| | | Pulmonary function was unchanged among referent group.; Pulmonary function was correlated with formaldehyde concentration in unadjusted regression analysis.; Pulmonary function improved after a 4-week holiday.
Reference: Löfstedt et al. (2011); Prospective study; follow-up of Löfstedt et al. (2009), Sweden.; Population: One of four foundries opted out of follow-up, plus 39 individuals (14 exposed workers and 25 referents) were lost to follow-up. 25 of 64 workers from 2009 study involved with Hot Box method; 55 of 134 referents from 2009 study working outside core-production and die-casting halls; not exposed to chemicals. Prevalence of childhood allergy lower in exposed than in referent in 2005 (4 vs. 31%, p < 0.05); higher prevalence of nasal symptoms among referent in 2005.; Exposure: Formaldehyde, isocyanic acid, and methyl isocyanate measurements on same day as spirometry.; Monoisocyanates: Mean of 4 to 5 15-minute samples; Formaldehyde: sampling over entire shift; Individual exposure estimated for 2001 and 2005 (mg/m^3^); levels 50% lower in 2005 (mean, range). | | | Decreased across shift pulmonary function reported in 2001 was correlated with decreased preshift pulmonary function in 2005.; VC r = 0.51, FEV r = 0.57, p < 0.05
| | | Preshift value and change in pulmonary function (percentage predicted), 2001−2005
| | | | 2001 | 2001−2005
| | | | Mean (SD) | Mean (SD) | Range
| | | VC
| | | Exposed | 93.3 (12.1) | −0.8 (4.2) | −11.2−6.5
| | | Referent | 93.9 (10.8) | −0.4 (3.8) | −11.0−5.9
| | | FEV_1_
| | | Exposed | 94.4 (11.6) | −1.3 (5.5) | −14.0−8.8
| | | Referent | 96.3 (11.6) | 0.3 (5.3) | −13.8−10.3
2001 | 0.098 (0.094) | 0.014−0.44 | Across shift change was not different between exposure groups (data not provided).; No association of formaldehyde with change in pulmonary function at follow-up in regression analysis (data not provided).
2005 | 0.045 (0.043) | 0.01−0.19
Correlation low between formaldehyde and either methyl isocyanate (r = −0.20) or isocyanic acid (r = 0.09); 61% of exposed were coremakers where formaldehyde levels were highest and isocyanate levels were lower.; Methods: Pulmonary function by spirometry (volumetric) using ATS guidelines. Pre- and postshift after 2 days with no exposure. Percentage predicted using Swedish reference. Regression analysis of formaldehyde adjusted for MIC, smoking, and childhood allergy.; Evaluation: ^a^; Low confidence; Limited sample size to detect small changes between 2001 and 2005; concern for survivor bias; coexposure to methyl isocyanate and isocyanic acid in exposed―unable to differentiate for comparisons of change from 2001 to 2005.

Within each grouping by study type, organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.3).

Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

b Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

##### Exposure in residences or school

###### Adults

Results among four studies of residential exposure among adults are difficult to compare because different methods were used to assess pulmonary function and two of the studies did not report results quantitatively (Norback et al., 1995; Broder et al., 1988c) (see Table 3-6). A cross-sectional study of residential formaldehyde exposure in a large, representative sample in Arizona observed a dose-dependent decline in PEFR among adult smokers at formaldehyde concentrations between 0.049 and 0.172 mg/m^3^, but not among the group as a whole (Krzyzanowski et al., 1990). Another study among elderly nursing home residents observed an elevated risk of low pulmonary function (defined as values falling in the lower 20% of the distribution) in association with formaldehyde concentrations above the median level measured in each nursing home (Bentayeb et al., 2015). The overall median and range of formaldehyde concentrations was 0.007 mg/m^3^ and 0.001−0.021 mg/m^3^, respectively, but the concentrations associated with elevated risks varied according to the median in each nursing home. Two additional studies that assessed effects of formaldehyde exposure on pulmonary function in primarily adult residential populations exposed to concentrations between 0.009 and 0.279 mg/m^3^ reported no associations, although the outcomes evaluated by each study were not directly comparable (Norback et al., 1995; Broder et al., 1988c).

The study by Krzyzanowski et al. (1990), which used the most thorough exposure-assessment protocol and included repeated measurements of PEFR (thus enhancing the ability to detect an association at the lower concentrations found in the homes) was interpreted with high confidence. The stability of the formaldehyde measurements over the two one-week sampling periods, some of which were separated by weeks or seasons, was confirmed by the authors (Quackenboss et al., 1989a; Quackenboss et al., 1989c) and reasonably represents exposures in the homes during the previous weeks and months (i.e., the etiologically relevant exposure window for pulmonary function status). Of the residential studies, only Krzyzanowski et al. (1990) examined effect modification by smoking status. Confidence in the regression results by Norbäck et al. (1995) is low because most of the measured formaldehyde concentrations were less than the LOD and the sensitivity of the study was low. Overall, results from the small set of studies suggest that participants 15 years of age and older did not experience declines in pulmonary function at average formaldehyde levels less than 0.05 mg/m^3^ (Krzyzanowski et al., 1990), however, declines may be experienced at lower concentrations among susceptible individuals (e.g., elderly, smokers) (Krzyzanowski et al., 1990; Bentayeb et al., 2015).

Table 3-6 Formaldehyde effects on pulmonary function among adults in residential settings

Study and design | Results
Reference: Krzyzanowski et al. (1990); Quackenboss et al. (1989c); (Quackenboss et al., 1989a); Cross-sectional study, Arizona, USA.; Population: A stratified random sample of 202 households of municipal employees, selected based on information about potential exposure (age of housing) and potential susceptibility obtained from an initial screening questionnaire. Households with children aged 5−15 years (613 adults and 298 children) were eligible for inclusion.; Mean age: >15 years old: 37 years, percentage male: 43.4%, percentage white: 70.4%, 24.4% current smokers.; Asthma prevalence: >15 years old: 12.9%.; Exposure: Sampling: two one-week samples (a subset in multiple seasons) from each individual’s kitchen, living area, and bedroom using passive sampling tubes (sensitivity 12 μg/m^3^ for 1 week, 15% accuracy).; Average formaldehyde concentration, 26 ppb [0.032 mg/m^3^],^b^ maximum 140 ppb, [0.172 mg/m^3^].^b^; The majority of subjects (83%) lived in homes with 2-week average concentrations below 40 ppb [0.049 mg/m^3^].^b^; Methods: Trained subjects measured peak expiratory flow rates (PEFRs) using Mini-Wright peak flow meters four times daily, in the morning, at noon, in the early evening, and before bed, for 2 weeks. The largest of three test results was recorded for each test period. Evening and morning values were used in analysis.; Analysis of PEFR in relation to indoor formaldehyde concentration, random effects model adjusting for asthma status, smoking status, SES, NO_2_ levels, episodes of acute respiratory illness, and time of day. Analysis performed separately for ages younger and older than 15 years.; Evaluation: ^a^; High confidence | Change in PEFR in L/min in relation to indoor formaldehyde, ages >15 years. (N = 526; 8,463 observations); β (SE)
| Formaldehyde (household mean) | | 0.09 (0.27)
| Morning formaldehyde (vs. bedtime) | | −5.9 (1.1)^a^
| Bedroom formaldehyde × morning | | −0.07 (0.04)^b^
| Morning × smoking | | −7.4 (2.6)^a^
| Bedroom formaldehyde × morning × smo king | | 0.59 (0.13)^a^
| Bedroom formaldehyde^2^ × morning × smoking | | −0.007 (0.001)^a^
| Constant | | 491.7 (8.5)
| ^a^p < 0.05, ^b^0.05 < p < 0.10
| In adults, only the morning PEFR values were affected by formaldehyde concentrations. Smoking status was shown to affect the relationship between PEFR and formaldehyde exposure.
Reference: Bentayeb et al. (2015); Cross-sectional study, 2009−2011; 7 European countries.; Population: 600 elderly residents (20 randomly selected per home) permanently living in randomly selected nursing homes (8 per city) in selected city in seven countries. Exclusion criteria stated (neurological or psychiatric disorders), 71.8% female, 62.8% ≥80 years old, 35% active smokers, 13.8% passive smoking.; Exposure: Measurements in common room; 1-week samples; also measured particulates, NO_2_, ozone, temperature, humidity and CO_2_; range of 1-week averages 0.001−0.021 mg/m^3^, median 0.006 mg/m^3^; categorical (low and high) based on median concentration in each nursing home.; Methods: Assessed by same team in all countries; medical visit and standardized questionnaire (European Community Respiratory Health Survey); lifetime COPD (ever told by doctor; spirometry (ATS/European Respiratory Society guidelines), percentage predicted. General estimating equations analysis, accounting for correlations within nursing homes; adjusted OR (95% CI) for risk of values <20% of distribution; stratification by presence of ventilation.; Evaluation: ^a^; Medium confidence; Confounding by coexposures was not assessed; median concentrations which defined low and high exposure categories were not reported. | Association of formaldehyde (cutpoint median in the nursing home) with pulmonary function < 20% of distribution among elderly nursing home residents
| | aOR^a^ | 95% CI
| FEV1 | 1.12 | 0.97−1.28
| FVC | 1.16 | 1.06−1.28
| FEV_1_/FVC < 70% | 0.46 | 0.12−1.66
| ^a^aOR: adjusted OR
| Stratification by poor (n = 436) or adequate (n = 105) ventilation.; FEV_1_ aOR (95% CI), 2.65 (1.29, 5.45).
Reference: Broder et al. (1988b, 1988c); Broder et al. (1988a); Cross-sectional study, February 1983−March 1984, Toronto, Canada.; Population: 1,726 occupants from 517 households with urea formaldehyde foam insulation (UFFI) identified from registry maintained by Urea Formaldehyde Foam Insulation Information and Coordination Centre, Consumer and Corporate Affairs, Canada (50% male, mean age 40 years, 80% over 16 years, 18% current smokers). 231 referent households (n = 720) selected at random from streets adjacent to UFFI households (49% male, mean age 35 years, 20% current smokers). Interviewers and respondents were not blinded with respect to the focus of the study or the presence of UFFI insulation.; Exposure: Formaldehyde sampling 5 hours on 2 successive days in central hallway, all bedrooms and in yard.; Inside: referent 0.035 ppm, range 0.006−0.112 ppm [0.043 mg/m^3^, range 0.007−0.138 mg/m^3^].^b^ 90% 0.061; UFFI 0.043 ppm, range 0.007−0.227 [0.053 mg/m^3^, range 0.009−0.279 mg/m^3^],^b^ 90% 0.073 ppm.; Outside: referent 0.005 ppm, UFFI 0.005 ppm.; Carbon dioxide sampled in central hallway and in yard (as indication of ventilation).; Methods: Questionnaire on symptoms and household characteristics, spirometry (minimum of three satisfactory tests, recorded largest value). Testing on ages 10 years and older.; Statistical comparisons by group and within group (multiple linear regression), adjusted for date of examination, gender, age, race, height, smoking, total hours spent in house per week.; Evaluation: ^a^; Medium confidence; For within group analyses: Results not presented for formaldehyde. Between group analysis: Small exposure contrast between exposure groups | Formaldehyde concentration within group was not associated with pulmonary function in multiple regression models (quantitative results not presented).; Between-group comparisons were not informative for formaldehyde associations because formaldehyde concentrations were comparable.
Reference: Norback et al. (1995); Cross-sectional study, Uppsala, Sweden.; Population: 88 men and women (47 with asthma symptoms and 41 without) who agreed to participate (57%) from a group of 154 eligible randomly selected from 488 preliminary subjects from general population of Uppsala in 1990, aged 20−44 years. Mean duration in homes 6 years (range 0.5−31 years).; Exposure: Field measurements: October 1991−April 1992.; Formaldehyde (one 2-hour sample) and guanine (house dust mites) in the bedroom at pillow height. Room temperature, air humidity, VOCs, respirable dust, and CO_2_ in living room and bedroom.; Formaldehyde mean (range):; 29 (<5−110 μg/m^3^) in homes of those with nocturnal breathlessness.; 17 (<5−60 μg/m^3^) in homes without symptoms.; Formaldehyde and VOCs concentrations were correlated and could not be evaluated in same regression model (no data presented).; Methods: Structured interview, spirometry (N = 82), blinded to exposure.; FEV_1_ spirometry, percentage predicted, multiple regression model, Kendall’s rank correlation test.; Evaluation: ^a^; Low confidence; Exposure: Sampling period less than one day. Low sensitivity, most exposed to concentration <LOQ; study population selected for high prevalence of asthma symptoms; correlated coexposure: VOCs. | FEV1 mean percentage predicted (SD): 106% (13%).; PEF mean variability (range): 5% (1−18%).; FEV1 percentage predicted, and PEF variability (during the day) were not associated with log-transformed formaldehyde concentration using Kendall’s rank correlation test (data not presented).

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.3). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

b Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

###### Children

A cross-sectional study of residential formaldehyde exposure in a large (298 children), population-based sample observed a linear relationship between increased formaldehyde exposure and lower peak expiratory flow rate (PEFR) averaged over 12 days among children aged 5 to 15 years exposed to average concentrations of 0.032 mg/m^3^ (26 ppb) (Krzyzanowski et al., 1990). Earlier reports showing preliminary results provided details about the methods used to sample formaldehyde concentrations and the stability of one-week averages separated in time. Formaldehyde concentrations measured during consecutive one-week sampling periods were compared to one-week averages separated by one or more weeks, including different seasons, in a subset of households Quackenboss et al. (1989c); (Quackenboss et al., 1989a). While correlation between the consecutive averages was higher than averages separated in time (consecutive weeks correlation coefficient = 0.9, R^2^ = 0.85; separated weeks R^2^ = 0.69, n=16), week to week differences were not statistically significantly different from zero indicating stability over time. These data support the conclusion that the average of two-week measurements represented stable formaldehyde levels present in the households over an extended period during the previous weeks and months (i.e., the etiologically relevant period for this outcome)(Krzyzanowski et al., 1990).

Since no trend was observed in the PEFR values over the 12 days of measurements, the 12-day average of PEFR in an individual was concluded to represent the current average pulmonary function for the children at the time of the study and the association with formaldehyde concentrations averaged over two one-week sampling periods was judged to indicate a “persistent” effect of formaldehyde exposure. As presented in Figure 3-6, the investigators reported a statistically significant decrease of −1.28 ± 0.46 L/minute in PEFR per ppb household mean formaldehyde. The figure shows the incremental decrement in PEFR measured at bedtime versus morning and shows differences in the morning among asthmatics and nonasthmatics. Asthmatic children (15.8% of the total) showed a steeper decline in PEFR in the morning at formaldehyde concentrations less than 0.049 mg/m^3^ (40 ppb). The analysis of multiple PEFR measurements resulted in an increased statistical power to detect an association at the lower formaldehyde levels present in the homes. Environmental tobacco smoke and NO_2_ exposure, as well as socioeconomic status, were not confounders of the association between formaldehyde exposure and PEFR in the children.

Figure 3-6 Association of PEFR measured at bedtime and in the morning with household mean formaldehyde concentration among children less than 15 years of age (Krzyzanowski et al., 1990)

Reproduced with permission.

Two other studies among children evaluated exposure to formaldehyde at home (Franklin et al., 2000) and at school (Wallner et al., 2012). The range of formaldehyde concentrations was similar to those in the homes evaluated by Krzyzanowski et al. (1990). While no associations were reported for FVC or FEV_1_ by either of the two studies that evaluated these measures (Wallner et al., 2012; Franklin et al., 2000), Wallner et al. (2012) also measured maximal expiratory flow at 50 or 75% of FVC (MEF_50_ and MEF_75_) and observed an approximate 3% decrease per standard deviation increase in formaldehyde concentration measured in elementary school classrooms. Several pollutants were evaluated by this study, and a few also were associated with MEF_75_. These pollutants, benzylbutylphthalate and polybrominated diphenylether congeners, both measured in dust, would be expected to originate from different sources than formaldehyde, and therefore, were not likely to be highly correlated with formaldehyde in air. The exposure contrast in the homes evaluated by Franklin et al. (2000) was relatively small, limiting the ability of the study to detect an association with formaldehyde. The interquartile range was 0.011−0.035 mg/m^3^, and concentrations between 0.062 and 0.107 mg/m^3^, the range in the higher exposure group, were found only in 10 homes.

The studies of formaldehyde exposure in homes and schools are limited in their sensitivity to detect a small reduction in pulmonary function associated with formaldehyde exposure at concentrations below 0.1 mg/m^3^ (see Table 3-7). However, a methodologically robust (high confidence) study reported an association with lower average peak expiratory flow rate (PEFR) measured multiple times per day over a 12-day period in this concentration range (Krzyzanowski et al., 1990). These findings are supported by lower levels of MEF_50_ and MEF_75_ (but not other measures) in association with increasing formaldehyde concentration in a separate medium confidence study (Wallner et al., 2012).

Table 3-7 Formaldehyde effects on pulmonary function among children in residential or school settings

Study and design | Results
Reference: Krzyzanowski et al. (1990); Quackenboss et al. (1989c); Quackenboss et al. (1989a); Cross-sectional study, Arizona.; Population: A stratified random sample of 202 households of municipal employees, selected based on information about potential exposure (age of housing) and potential susceptibility obtained from an initial screening questionnaire. Households with children aged 5−15 years (613 adults and 298 children) were eligible for inclusion.; Mean age: <15: 9.3 years, percentage male: <15: 50.2%, percentage white: <15: 67.3%, Asthma prevalence: <15: 15.8%.; Exposure: Sampling: two 1-week samples (a subset in multiple seasons) from each individual’s kitchen, living area, and bedroom using passive sampling tubes (sensitivity 12 μg/m^3^ for 1 week). Average concentration, 26 ppb [0.032 mg/m^3^],^b^ maximum 140 ppb, (0.172 mg/m^3^).^b^; The majority of subjects (83%) lived in homes with 2-week average concentrations below 40 ppb (0.049 mg/m^3^).^b^; Methods: Trained subjects measured peak expiratory flow rates (PEFRs) using Mini-Wright peak flow meters four times daily, in the morning, at noon, in the early evening, and before bed, for 2 weeks. The largest of three test results was recorded for each daily test period (e.g., morning, bedtime). Evening and morning values were used in analysis.; Analysis of PEFR in relation to indoor formaldehyde concentration, random effects longitudinal model including morning and bedtime formaldehyde concentration, adjusting for asthma status, smoking status, environmental tobacco smoke, socioeconomic status, NO_2_ levels, episodes of acute respiratory illness, and time of day. Analysis performed separately for ages younger and older than 15 years.; Evaluation: ^a^; High confidence | Change in PEFR (L/min) in relation to indoor formaldehyde, random effects longitudinal model, ages ≤15 (N = 208; 3,021 observations)
| Factor | | b (SE)
| Formaldehyde (household mean, ppb) | | −1.28 (0.46)^a^
| Morning formaldehyde (vs. bedtime) | | −6.1 (3.0)^a^
| Bedroom formaldehyde *morning | | 0.09 (0.15)
| Bedroom formaldehyde squared *morning | | 0.0031 (0.0015)^a^
| Morning*asthma | | 4.59 (9.60)
| Bedroom formaldehyde*morning* asthma | | −1.45 (0.53)^a^
| Bedroom formaldehyde squared *morning*asthma | | 0.031 (0.006)^a^
| Constant | | 349.6 (13.2)
| ^a^p < 0.05, ^b^0.05 < p < 0.10
| PEFR decreased in children as formaldehyde concentrations increased with a difference noted between the measurements taken in the morning vs. bedtime. The morning PEFR was further decreased in children with asthma.
Reference: Wallner et al. (2012); Cross-sectional study; Austria.; Population: 433 children (aged 6−10 years) with spirometry of 596 eligible (72.7%) in two classrooms each at 9 of 19 schools that volunteered to participate in study (50% male). 53% of the children were exposed to environmental tobacco smoke at home.; Exposure: Pollutant measurements for 252 agents: 2 samples in each classroom, 1 per season (autumn, spring).; Formaldehyde: 24-hour sampling period, all values > LOQ 34 chemicals selected for statistical analysis were those with substantial variation across schools based on an arbitrarily selected criterion (ratio of between-school variance to the pooled within-school variance >4).; Methods: Questionnaire completed by parents, spirometry assessed at school between 8:30 am and 12:30 pm by trained technician, ATS protocol except 6-second minimum exhalation time (not feasible in children). Values expressed as percentage of reference based on age, gender, height, and weight. Regression of log-transformed values on mean concentration of chemical adjusted for education and occupation of parents, urban/rural residence, and # smokers at home. No adjustment of statistical significance criterion for multiple comparisons (exploratory).; Evaluation: ^a^; Medium confidence; No adjustment for coexposures in classroom that were also associated with pulmonary function, but correlation not anticipated. | Percentage change in pulmonary function (95% CI) per 1 SD change in formaldehyde concentration
| | % Change | 95% CI
| FVC^a^ | −0.94 | −3.29, 1.35
| FEV_1_^a^ | −2.16 | −4.80, 0.41
| MEF_75_^b^ | −3.31 | −6.6, −0.08
| MEF_50_ | −2.60 | −4.31, −0.91
| ^a^Associations with ethylbenzene, m-, p-xylene, and o-xylene in air, tris (1,3-dichlor-2-propyl)-phosphate in particulate matter, and benzylbutylphthalate (FEV_1_ only) and polybrominated diphenylether congeners in dust were statistically significant.; ^b^Associations with benzylbutylphthalate and polybrominated diphenylether congeners in dust also were statistically significant.
Reference: Franklin et al. (2000); Cross-sectional study, Australia.; Population: 224 healthy children (116 girls, 108 boys) with no current or history of upper or lower respiratory tract disease based on responses to respiratory health questionnaire and household inventory distributed through local primary schools.; Age provided by author: <50 ppb, 9.5 years (SD 1.6); ≥50 ppb, 9.2 years (SD 1.9).; Exposure: 3 to 4-day passive samples collected in the child’s bedroom and the main living area of the house, average of both rooms; 214 homes.; TWA categorized into two groups: <50 ppb (0.062 mg/m^3^)^b^ and ≥50 ppb (10 homes).; Additional information from author:; Mean (SD): 20.1 ppb (15.6) (0.025 mg/m^3^)^a^; range ND−86.6 ppb (ND−0.107 mg/m^3^)^b^.; Median (IQR): 15.6 ppb (0.019 mg/m^3^)^a^ (range 9.2−28.1) (0.011−0.035 mg/m^3^).^b^; Methods: Clinical respiratory measures obtained at children’s hospital. Measured spirometry (ATS guidelines), exhaled nitric oxide (eNO), and skin prick tests for seven common allergens.; Evaluation: ^a^; Medium confidence; Limited exposure contrast; few subjects in high exposure group. | Mean pulmonary function (SD) by exposure group^a^
| | <50 ppb | ≥50 ppb
| FVC (L) | 2.21 (0.55) | 2.18 (0.46)
| Percentage predicted | 99.1 (10.2) | 101.4 (7.3)
| FEV_1_ | 1.89 (0.46) | 1.83 (0.24)
| Percentage predicted | 96.3 (11.1) | 97.2 (5.4)
| FEV/FVC (%) | 89.1 (9.2) | 93.1 (11.3)
| ^a^Not reported; data provided to EPA by author; percentage predicted based on age, sex, and height.
| eNO levels by exposure category
| HCHO (ppb) | eNO (ppb) | Range
| ≥50 | 15.5 | 10.5–22.9
| <50 | 8.7^a^ | 7.9–9.6
| ^a^p = 0.002, linear regression adjusted for age, atopic status.

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.3).

Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

b Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

##### Panel studies of changes in pulmonary function among anatomy/pathology students

Three panel studies examined pulmonary function changes over the course of 10 weeks, 12 weeks, and 7 months among anatomy students exposed to formaldehyde, with average concentrations ranging from 0.12 to 6.2 mg/m^3^ intermittently [once or twice a week: (Uba et al., 1989; Kriebel et al., 1993; Kriebel et al., 2001); see Table 3-8]. The primary source of formaldehyde exposure in the laboratory air was formalin, a preservative composed of a mixture of formaldehyde (37%) and methanol (14%). Methanol is not expected to be associated with pulmonary function deficits and would not be a strong confounder in these studies (U.S. EPA, 2013). One study that measured pulmonary function using spirometry did not observe statistically significant declines over 7 months (Uba et al., 1989). Two studies by the same research group using repeated peak expiratory flow measures taken by students trained in the procedure at multiple points during the lab sessions suggested a dose-dependent average decline in PEF over 2 to several weeks related to concentration averaged over the entire duration, as well as reductions during dissections (Kriebel et al., 1993; Kriebel et al., 2001). Cumulative exposure (ppm-minutes) summed over all previous weeks was not a significant predictor of changes in pulmonary function. The measurement of multiple measures of PEF per student in the studies by (Kriebel et al., 1993; Kriebel et al., 2001) increased the precision of the mean value and, consequently, the statistical power to detect a significant change. Evidence from these panel studies provides support that formaldehyde exposure during anatomy labs results in pulmonary function declines over several weeks duration, although interpretation of the analyses by both Kriebel et al. and Uba et al. is complicated by the consideration that class attendance as well as formaldehyde concentrations decreased over the semester in the studies (Uba et al., 1989; Kriebel et al., 2001).

Table 3-8 Formaldehyde effects on pulmonary function in panel studies among anatomy or pathology students

Study and design | Results
Reference: Uba et al. (1989); Panel study, California; Population: 96 medical students (72.5% participation) during a 7-month anatomy class meeting twice a week for 4 hours. Mean age: 24.3 years, 88% white, 73.8% male, nonsmokers, 12 asthmatics.; Exposure: Personal sampling monitors (impingers) in the breathing zone, 32 samples during different class periods in 7-month period. Short-term samples (N = 16) for peak concentrations during dissection.; Range of TWA formaldehyde: below LOD (0.05 ppm) to 0.93 ppm (0.06 to 1.14 mg/m^3^)^a^; Monthly averages in September, October, and May: 0.6, 0.8, and 0.1 ppm (0.74, 0.98, and 0.12 mg/m^3^),^a^ respectively.; Peak concentrations: During dissection: mean 1.9 ppm (2.3 mg/m^3^)^,a^ range 0.1 to 5.0 ppm (0.12 to 6.1 mg/m^3^),^a^ observing dissection: mean 1.2 ppm (1.5 mg/m^3^)^a^ range 0.2 to 2.0 ppm (0.25 to 2.5 mg/m^3^)^a^; Methods: Pre- (noon) and postlab spirometric measures (ATS methods) taken before the class began, after the first 2 weeks, and after 7 months.; Analyzed using repeated measures ANOVA, adjusted for sex.; Evaluation: ^a^; High confidence | Pulmonary function by test day (mean ± SD) (N = 96)
| Before exposure | FVC (L) | 5.246 ± 1.025
| (Day 1) | FEV_1_ (L) | 4.379 ± 0.846
| | FEF_25−75_ (L/sec) | 4.492 ± 1.216
| | FEV_1_/FVC | 0.835
| 2 Weeks | FVC (L) | 5.277 ± 1.027
| | FEV_1_ (L) | 4.409 ± 0.824
| | FEF_25−75_ (L/sec) | 4.484 ± 1.151
| | FEV_1_/FVC | 0.836
| 7 months | FVC (L) | 5.308 ± 1.027
| | FEV_1_ (L) | 4.399 ± 0.823
| | FEF_25−75_ (L/sec) | 4.392 ± 1.198
| | FEV_1_/FVC | 0.829
Reference: Kriebel et al. (2001) Panel study, USA; Population: 51 gross anatomy students (out of 54 total) during a 12-week class meeting once per week for 2.5 hours. Mean age: 24.9 years, 23.7% male, two current smokers, four with history of asthma.; Exposure: Continuous monitoring in six homogenous sampling zones (LOD = 0.05 ppm). 12-minute work-zone concentrations calculated per student using sampling data and recorded work locations.; Geometric mean concentration: 0.7 ppm (0.9 mg/m^3^)^a^ (GSD: 2.13 ppm). Peak 12-min concentration: 10.91 ppm (13.4 mg/m^3^).^a^; Average concentration: 1.1 ppm (1.35 mg/m^3^)^a^ (SD = 0.56 ppm). Concentrations decreased over 12-week semester.; Methods: Spirometry (FEV_1_, FVC) using ATS criteria before 1st exposure and during 10th week. Pre- and post-lab PEF measurements obtained for at least 1 week for 38 students. PEF as fraction of value before 1st lab session; individual pre-lab and cross-lab change data analyzed together in relation to recent, average, and cumulative formaldehyde in single generalized estimating equations model. Generalized estimating equations regression adjusted for cold on lab day.; Evaluation: ^a^; Medium confidence (↓); Attrition and declining concentration over course―bias to healthy individuals and toward null | Exposure metrics: Recent exposure = mean concentration during 2.5-hour lab;; cumulative exposure = ppm-minutes for all previous weeks;; past average exposure: Cumulative exposure divided by total number of minutes of exposure.
| PEF as fraction of baseline (before 1st lab) (L/s per ppm)
| | ß (SE) | p-value
| Recent exposure | −1.05 (0.33) | 0.002
| Recent exposure *ln(week) | 0.69 (0.24) | 0.004
| Past average exposure | −0.52 (0.30) | 0.08
| Cold on lab day | −1.67 (0.41) | 0.001
| No association with cumulative exposure. Pulmonary function among asthmatics not different.
Reference: Kriebel et al. (1993) Panel study, USA; Population: 24 clinical anatomy students (out of 25 total) during a 10-week anatomy class meeting once a week for 3 hours.; Mean age 26, 42% male, 1 current smoker, five reported history of asthma.; Exposure: Personal samples in the breathing zone, 1−1.5 hours sampling periods.; Formaldehyde concentration geometric mean: 0.73 ppm (0.9 mg/m^3^),^a^ GSD 1.22; range: 0.49−0.93 ppm (0.6−1.14 mg/m^3^); 8 samples. No trend in concentrations over semester.; Pentachlorophenol: ND (LOD = 83 μg/m^3^).; Methods: PEF measured by trained students pre- and postlab and 1−3 times during lab using Mini-Wright peak flowmeters. Mean absolute value (SD) pre- and cross-lab change in pulmonary function analyzed in separate models using multivariate linear models, including asthma, asthma × week, eye and nose or throat symptoms.; Evaluation: ^a^; Medium confidence; Limited sample size | PEF (L/min) during course (mean ± SD) (n = 20)
| Weeks 1−2 | PEF (L/min) | 538.9 (86.9)
| Weeks 9−10^a^ | PEF (L/min) | 529.4 (88.4)
| Weeks 24−25 | PEF (L/min) | 536.6 (86.2)
| ^a^End of course.
| Decrement over 10-week course, β = −2.7 ± 1.1 L/min per week; p = 0.01, Model included asthma, asthma × week, eye symptoms, nose symptoms.

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.3). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Summary of Human Evidence Synthesis Judgments on Pulmonary Function

The following factors, in particular the observed dose-dependence, were influential to the synthesis judgment that the human studies of long-term (months to years) formaldehyde exposure provide moderate evidence of formaldehyde exposure-induced decrements in pulmonary function.

- Consistency and Study Confidence: The majority of the numerous high and medium confidence studies reported consistent decrements in pulmonary function in relation to formaldehyde exposure; in different settings including occupational, residential and anatomy labs. Associations with pulmonary function deficits were found in occupational studies with longitudinal designs as well as cross-sectional analyses. Although one panel study among anatomy students did not report declines related to formaldehyde exposure, evidence from two panel studies conducted by one investigator group provides support that formaldehyde exposure during anatomy labs results in pulmonary function declines over several weeks duration.
- There was less consistency across studies for deficits in individual measures of pulmonary function (e.g., FEV_1_, FVC or FEF_25-75_).
- Dose-Response: Demonstrated exposure-response trends were observed in four high or medium confidence studies. In addition, well-conducted studies of individuals likely to be more susceptible to these effects (e.g., children; persons with asthma, elderly) showed that these effects occurred in these persons at lower formaldehyde levels (<0.05 mg/m^3^) in analyses that ruled out confounding by smoking status, environmental tobacco smoke and NO_2_ exposure.
- Strength and Precision: Decrements in FEV_1_, FVC or FEF_25-75_ of 3% or greater were reported by several studies, although many analyses were imprecise which reduces certainty to a limited extent.

In addition to the judgment above, a general inference can be drawn based on the human studies. Specifically, children and individuals with compromised respiratory health are likely to be more sensitive to the effects of formaldehyde inhalation on pulmonary function.

#### Animal Studies

##### Summary of Animal Evidence Synthesis Judgments

Animal studies of apical pulmonary function endpoints were not formally evaluated (see Section 2.2.3). However, the mode of action information (discussed below) describing how formaldehyde inhalation might result in decrements in pulmonary function is primarily based on experimental studies in animals, which supports the biological plausibility of such effects and, by itself, is interpreted to provide slight animal evidence for effects on pulmonary function.

#### Evidence on Mode of Action

Although an MOA for formaldehyde-related effects on pulmonary function remains incompletely defined, it is likely that it involves the indirect activation of sensory nerve endings in the lower respiratory tract (LRT), increases in airway eosinophils, or both (see Figure 3-7). Moderate evidence exists for the mechanistic changes that could be directly related to decrements in pulmonary function (e.g., inflammatory changes in airway structure), and moderate or robust evidence supports the linkages between events in this pathway. However, the initial cellular or tissue modifications that ultimately lead to these later events are not completely understood and given the limitations of the available studies (see Appendix B.3.6), it is unclear whether certain events would be triggered at low-exposure levels. It is also possible that structural and functional changes in the upper respiratory tract (URT) might contribute to decreased pulmonary function; however, these possibilities are considered unlikely to be significant drivers of these effects (see additional discussion below). Overall, the airway inflammatory changes in the LRT, which may be at least partially related to indirect activation of sensory nerve endings, is judged as likely to be an incomplete mechanism by which formaldehyde inhalation could cause decreased pulmonary function. As the mechanistic event(s) critical to understanding the observed relationship remain unknown, including how sensory nerve endings in the LRT might be stimulated without distribution of inhaled formaldehyde to the LRT, it is expected that important insights would be gained from additional studies, particularly those testing longer exposure durations. Although much of the mechanistic support is from studies in experimental animals, it is expected that related mechanisms are operant in exposed humans and could contribute to the consistent decrements in pulmonary function observed in the available epidemiology studies. Variation in sensitivity is likely to be affected by underlying respiratory health status and the exposure history of the individuals, including exposure to known allergens.

Figure 3-7 Possible mechanistic associations between formaldehyde exposure and decreased pulmonary function

An evaluation of the formaldehyde exposure-specific mechanistic evidence informing the potential for formaldehyde exposure to cause respiratory health effects (see Table 3-9 and Appendix C.7) identified these sequences of mechanistic events as those most directly relevant to interpreting effects on pulmonary function. Evidence of airway inflammatory changes, including eosinophil, is considered as likely to represent an incomplete mechanism by which formaldehyde inhalation could cause decreased pulmonary function, although whether certain events occur at lower exposure levels is unclear, and other unexplored mechanistic events are expected to contribute. URT modifications, primarily structural changes (bottom pathway), may also contribute; however, this is not interpreted as likely to be a significant contributing mechanism.

The most plausible support for a mechanism(s) that explains the observed decreases in pulmonary function includes evidence of increased airway eosinophils and other immunogenic changes that could be attributed to sensory nerve activation in the LRT (presumably, the vagus nerve) of exposed rodents, although the potential involvement of LRT sensory nerve stimulation is poorly studied (i.e., slight evidence). It is expected that LRT sensory nerve activation would be reliant on a secondary response to TRP channel-activating stimuli increased in the LRT via indirect mechanisms, such as increased LRT oxidative stress or inflammatory mediators, or both, released from activated immune cells. This response is unlikely to result from direct stimulation of the nerve by inhaled formaldehyde or in response to cellular damage, as inhaled formaldehyde is unlikely to reach the LRT in appreciable amounts and overt epithelial damage in the LRT is not supported by the available evidence (see Appendix A.5.6). While it might also be explained by a central trigeminal-to-vagal neural reflex response to irritation of the URT (i.e., a “nasobronchial” reflex^17^), the existence of this reflex in humans is debated and a clear scientific consensus does not exist (Togias, 1999, 2004; Sahin-Yilmaz and Naclerio, 2011; Giavina-Bianchi et al., 2016).

Stimulation of sensory nerve endings can cause a localized release of neuropeptides. Accordingly, moderate evidence supports that formaldehyde exposure results in increased LRT neuropeptides, including substance P, typically at formaldehyde concentrations ≥2.5 mg/m^3^, with coherent moderate evidence for rapid activation of the primary receptor for substance P, the neurokinin (NK1) receptor, after acute exposure to higher formaldehyde levels. Further, the activation of the substance P pathway has been experimentally linked to formaldehyde-induced leakage of the LRT microvasculature. Airway edema and related inflammatory structural changes (i.e., in airway bronchi), which have been reported in experimental animals following short-term formaldehyde exposures ranging from >0.3 to >3 mg/m^3^ and which appear to be exacerbated by prior allergen exposure, may represent consequences of increased microvascular leakage and inflammation (see below). To date, potential experimental linkages between these structural changes and sensory nerve stimulation or substance P signaling have not been studied after formaldehyde exposure. Similarly, while these changes could lead to an increased permeability to bronchoconstrictors such as histamine, and while substance P itself can increase the responsiveness of airway smooth muscle, these endpoints were generally unexamined in the available studies. Any or all of these immunogenic changes could plausibly contribute to airway narrowing or obstruction and affect pulmonary function, although airway obstruction would generally be expected to require much higher exposure levels or effects that cumulate over an extended period of time. Importantly, however, the majority of the evidence available to inform these immunogenic changes is from studies of short-term exposure.

Substance P and NK1R signaling has been implicated in establishing the successful recruitment and adhesion of eosinophils to inflamed airways, and it can promote immune cell survival and activation through the release of cytokines and chemokines (Mashaghi et al., 2016). Moderate evidence for an association between formaldehyde exposure and increases in LRT eosinophils was identified, including amplification of the response of these cells in rodents previously exposed to allergens. Considering the evidence in the respiratory tract, a generalized increase in airway eosinophils after formaldehyde exposure is supported by robust evidence. Increased airway eosinophils have been reported following exposure of laboratory rodents for several weeks at effective concentrations above 0.5 mg/m^3^, with increases generally not being observed following acute exposure. Recruitment of eosinophils to the airways might be related to the moderate evidence for LRT markers of oxidative stress, as eosinophils can release toxic mediators, including lipid-active factors and reactive oxygen species (again noting that it is considered more likely that any oxidative stress increases would result from changes in inflammatory factors and immune cells in the LRT, rather than LRT epithelial damage). However, the activation characteristics of the recruited airway eosinophils, including factors released, have not been defined, preventing a more complete understanding of whether and how these cells might decrease pulmonary function in these contexts.

As noted above, modifications to the URT respiratory epithelium could also result in changes that might indirectly affect pulmonary function. Such modifications include potential effects on immunological functions, such as an altered release of secreted factors from damaged epithelial cells, or effects on structural functions (e.g., modified clearance or barrier processes due to dysfunction of the mucociliary apparatus or cell type transitions or narrowing of upper airways due to inflammation or proliferation). If increased URT cytokines or other soluble mediators were to reach the LRT, they could contribute to decreased pulmonary function through airway hyperreactivity or hypersensitivity to challenges such as allergen exposure (Hulsmann and Dejongste, 1996). However, it is expected that most immune factors released from URT respiratory epithelial cells are tightly controlled and locally acting, and that modest increases would be unlikely to have significant effects on the lower airways and lungs. Similarly, it is reasonable to presume that physical modifications to the URT would need to be severe to cause a noticeable change in function, which would not be expected with typical exposure scenarios. Direct, formaldehyde-specific examinations of any such associations between the robust evidence for structural URT changes and LRT effects were not identified, further limiting the interpretation of this potential association.

While evidence for some events at low formaldehyde levels (e.g., <1 mg/m^3^) exists, some of the more convincing associations have only been tested at high formaldehyde concentrations. Additionally, the supporting mechanistic evidence is generally from studies of short-term (i.e., days to weeks) exposure. Therefore, the relevance and sensitivity of the proposed mechanistic pathways to chronic, low-level exposure scenarios is uncertain. It is also presumed that several important mechanistic events are currently unidentified. In particular, the initial effects of formaldehyde exposure that lead to the LRT changes remain undefined, although speculative, untested scenarios explaining the associations can be hypothesized based on the data available. Similarly, no explanation exists for the observed exaggerated effects on some mechanistic events following prior allergen exposure. Overall, however, although a definitive MOA has not been fully identified, several contributing mechanistic events interpreted with moderate or robust evidence appear to impact pulmonary function and, taken together, these data provide support for the biological plausibility of formaldehyde exposure-induced decreases in pulmonary function (see Table 3-9).

Table 3-9 Mechanistic evidence most informative to the occurrence of decreased pulmonary function after formaldehyde inhalation

Endpoint | Endpoint-specific findings and confidence | | Summary of evidence | Conclusion
Modifications in the nose and upper airways
Modification of biological macromolecules; (see Appendix C.1 and C.3 on ADME and Genotoxicity for additional detail) | High or Medium | Human: No direct evidence [note: binding of formaldehyde to albumin and other soluble proteins in human mucus has been demonstrated in vitro, e.g., (Bogdanffy et al., 1987)]; hemoglobin adducts are observable after months-to-years exposure at ^~^0.2 mg/m^3^ (Bono et al., 2012). | Consistent with its known chemistry, formaldehyde can modify cellular macromolecules, including DNA, and interact with soluble factors such as albumin and glutathione, after exposure to low levels (e.g., <0.5 mg/m^3^) across a wide range of exposure durations. | Robust
Modification of biological macromolecules; (see Appendix C.1 and C.3 on ADME and Genotoxicity for additional detail) | High or Medium | Animal: Multiple animal studies testing various exposure durations demonstrate that inhaled formaldehyde can bind and modify biological macromolecules, which is consistent with the known biological reactivity of formaldehyde; evidence includes increased DNA-protein crosslinks (DPXs), hydroxymethyl (hm) DNA adducts, and reactions with glutathione [e.g., increased DPXs are observed at ≥0.37 mg/m^3^ (Casanova et al., 1989)]; and hmDNA adducts and protein adducts are observed at ≥0.86 mg/m^3^ (Lu et al., 2010a; Lu et al., 2011; Edrissi et al., 2013b). | | Robust
Modification of biological macromolecules; (see Appendix C.1 and C.3 on ADME and Genotoxicity for additional detail) | Low | N/A: Sufficient information for ‘robust’ from high or medium confidence studies. | | Robust
Impaired mucociliary function; (see Appendix C.7 for additional detail and discussion) | High or Medium | Human: Decreased mucus flow at ≥0.3 mg/m^3^ after acute exposure and pathological changes in mucociliary clearance in workers at mean exposed levels of 0.25−0.26 mg/m^3^ after chronic exposure (Holmström and Wilhelmsson, 1988; Andersen and Molhave, 1983). | Decreased mucus flow and ciliary beat, and impaired clearance, in humans and rats at ≥0.25 and ≥2.5 mg/m^3^, respectively (observed across exposure durations), eventually leading to cilia loss. | Robust
Impaired mucociliary function; (see Appendix C.7 for additional detail and discussion) | High or Medium | Animal: Mucociliary function was generally unaffected at <0.57 mg/m^3^ after short-term exposure, with minor changes noted at the next exposure level, around 2.5 mg/m^3^; robust changes were observed at the next highest concentrations tested, ≥7.27 mg/m^3^ after acute or short-term exposure; there was a general lack of recovery with longer exposure duration (e.g., (Morgan et al., 1986a; Morgan et al., 1986c; Monticello et al., 1989); see Appendix C.7 and B.3.6). | Decreased mucus flow and ciliary beat, and impaired clearance, in humans and rats at ≥0.25 and ≥2.5 mg/m^3^, respectively (observed across exposure durations), eventually leading to cilia loss. | Robust
Impaired mucociliary function; (see Appendix C.7 for additional detail and discussion) | Low | Human: Increases in ciliary activity at 1.23 mg/m^3^ in dissociated human nasal epithelial cells (Wang et al., 2014b), with decreased ciliary beating frequency in human epithelial cells at ≥3.46 mg/m^3^ (Wang et al., 2014b; Schafer et al., 1999): in vitro, acute exposure. | Suggestive of decreased ciliary beat and ciliastasis at ≥5 mg/m^3^ in humans and animals with acute exposure, and ciliary damage at ≥0.5 mg/m^3^ with short-term exposure; usually preceded by initial effects including slight increases in activity. | Robust
Impaired mucociliary function; (see Appendix C.7 for additional detail and discussion) | Low | Animal: Ciliastasis and mucostasis after acute exposure in vitro (Morgan et al., 1984): frog palates at ≥5.36 mg/m^3^ (with early activity increases, even at 1.69 mg/m^3^); structural cilia changes were also observed (Monteiro-Riviere and Popp, 1986): short-term exposure at ≥0.5 mg/m^3^; and (Abreu et al., 2016): acute exposure at 0.25, but not 1.2−3.7 mg/m^3^. | | Robust
Structural change in URT mucus membrane or nasal obstruction | High | Human: Membrane hypertrophy, atrophy, rhinitis (Lyapina et al., 200 4): chronic (years) exposure at 0.87 mg/m^3^. | Mucus membrane damage and swelling in humans at 0.87 mg/m^3^ with chronic exposure. | Moderate (particularly in persons with nasal damage)
Structural change in URT mucus membrane or nasal obstruction | High | Animal: None | Mucus membrane damage and swelling in humans at 0.87 mg/m^3^ with chronic exposure. | Moderate (particularly in persons with nasal damage)
Structural change in URT mucus membrane or nasal obstruction | Low | Human: Data suggest increased mucosal swelling, nasal obstruction or rhinitis in workers by (Holmström and Wilhelmsson, 1988): chronic exposure at 0.26 mg/m^3^, and (Norback et al., 2000): short-term exposure at ≤0.016 mg/m^3^, which did not increase in severity with longer exposure; increased mucosal swelling was also noted in symptomatic nasal distress patients, but not healthy controls (Falk et al., 1994): acute (2-hr) exposure at ≥0.073 mg/m^3^. | Observations at ≤0.26 mg/m^3^ in humans or at >3.5 mg/m^3^ in rats support data from the chronic duration study and suggest increased acute vulnerability of people with a prior nasal condition. | Moderate (particularly in persons with nasal damage)
Structural change in URT mucus membrane or nasal obstruction | Low | Animal: Rhinitis and necrosis in rats after acute or short-term exposure, generally at ≥3.5 mg/m^3^ (see Appendix C.6 and C.7). | Observations at ≤0.26 mg/m^3^ in humans or at >3.5 mg/m^3^ in rats support data from the chronic duration study and suggest increased acute vulnerability of people with a prior nasal condition. | Moderate (particularly in persons with nasal damage)
URT epithelial damage or dysfunction (see Section 3.2.4 for additional detail) | High or Medium | Human: Indirect data indicating epithelial damage, including loss of ciliated cells, in occupational studies at 0.1 to >2 mg/m^3^ (Holmström and Wilhelmsson, 1988; Holmstrom et al., 1989c; Edling et al., 1987a, 1988; Ballarin et al., 1992), with some equivocal findings (Boysen et al., 1990); however, these histopathological symptom scores included hyperplasia and metaplasia, which complicate interpretation. | Duration-dependent epithelial damage, typically at ≥2.5 mg/m^3^ in subchronic or chronic rat studies, and with supportive indirect findings from human studies at 0.1−0.2 mg/m^3^, generally correlates with inhibited mucociliary activity. | Robust
URT epithelial damage or dysfunction (see Section 3.2.4 for additional detail) | High or Medium | Animal: Increased epithelial damage and related nasal lesions [e.g., (Andersen et al., 2010)]: duration dependent, typically ≥2.46 mg/m^3^ in subchronic and chronic studies, with general correlation with inhibited mucociliary activity; goblet cell loss noted in monkeys (Monticello et al., 1989): short-term (1 week) exposure at 7.38 mg/m^3^; indirect evidence mRNA or miRNA changes associated with apoptosis (Rager et al., 2013; Rager et al., 2014): short-term (2-d in macques or 28-d in rats) exposure at ≥2.46 mg/m^3^. | | Robust
URT epithelial damage or dysfunction (see Section 3.2.4 for additional detail) | Low | Human: None | Studies suggest that nasal epithelial damage is increased, even in short-term studies, at ≥2.5 mg/m^3^. | Robust
URT epithelial damage or dysfunction (see Section 3.2.4 for additional detail) | Low | Animal: Goblet cell damage and decreased junctional proteins between epithelial cells in rats (Arican et al., 2009): subchronic (12-week) exposure at 18.5 mg/m^3^; mRNA changes in DNA repair genes in rats (Andersen et al., 2010): short-term (1-week) exposure, but not longer (4- to 13-week) durations at ≥12.3 mg/m^3^; rhinitis and necrosis in rats after acute or short-term (1- to 3-d) exposure at ≥3.94 or 4.43 mg/m^3^. | Studies suggest that nasal epithelial damage is increased, even in short-term studies, at ≥2.5 mg/m^3^. | Robust
↑ URT oxidative stress | See Section 3.2.1 for a description of the direct and indirect evidence of elevated reactive oxygen species (ROS) in the URT, possibly at very low concentrations (e.g., at >0.066 mg/m^3^) with prolonged exposure. | | | Moderate
↑ Neuropeptide release | High or Medium | Human: None | Indirect evidence after subchronic exposure in a mouse study at 2.46 mg/m^3^; Indirect evidence for acute activation of the receptor for substance P in rats at >18 mg/m^3^. | Moderate (for ↑ neuropeptides); Moderate (for NK1R stimulation); (note: relevant to both URT and LRT)
↑ Neuropeptide release | High or Medium | Animal: Increased substance P in plasma in mice (Fujimaki et al., 2004b): subchronic exposure at 2.46 mg/m^3^; microvascular leakage in rats (Ito et al., 1996): acute exposure to 18.45 mg/m^3^; this was inhibited by NK1 receptor antagonists (note: substance P binds NK1R). | Indirect evidence after subchronic exposure in a mouse study at 2.46 mg/m^3^; Indirect evidence for acute activation of the receptor for substance P in rats at >18 mg/m^3^. | Moderate (for ↑ neuropeptides); Moderate (for NK1R stimulation); (note: relevant to both URT and LRT)
↑ Neuropeptide release | Low | Human: Substance P in nasal lavage (in URT) is increased in human volunteers with ocular exposure (He et al., 2005): 4-d (5-min/d) exposure at 3 mg/m^3^, not 1 mg/m^3^. | Data suggest formaldehyde activates TRP channels on sensory neurons, leading to release of CGRP and substance P, with acute or short-term exposure at >1 mg/m^3^. An inhibitor study in isolated rat LRT tissue provides evidence of NK1R involvement, although the relevant inhalation exposure levels are unknown. | Moderate (for ↑ neuropeptides); Moderate (for NK1R stimulation); (note: relevant to both URT and LRT)
↑ Neuropeptide release | Low | Animal: In URT models, formaldehyde stimulates release of calcitonin gene-related protein (CGRP) in in vitro models relevant to inhalation exposure of the URT (Kunkler et al., 2011); experiments using the related chemical, acrolein, suggest this is TRPA1-mediated (Kunkler et al., 2011).; In LRT models, inhibition of substance P receptor (NK1R) inhibited formaldehyde-induced currents in isolated rat trachea (Luo et al., 2013); increased substance P and CGRP in mouse BAL, both amplified with ovalbumin (OVA) sensitization, and both involved TRP activation (Wu et al., 2013): short-term exposure at 3 mg/m^3^. | | Moderate (for ↑ neuropeptides); Moderate (for NK1R stimulation); (note: relevant to both URT and LRT)
Nasal cellular inflammatory response | High or Medium | Human: None | Cellular infiltration observed by histology, primarily neutrophils, but indirectly supporting other immune cell infiltration, in short-term animal studies at 7.38 mg/m^3^. Indirect evidence of increases in granulocytes (and possibly lymphocytes) at 2.46 mg/m^3^ with short-term exposure. | Moderate (↑ granulocytes: neutrophils and eosinophils); (Note: data on lymphocytes were indeterminate)
Nasal cellular inflammatory response | High or Medium | Animal: Increased inflammatory response, mostly neutrophils but also mention of lymphocytes and other inflammatory cells (e.g., assumed monocytes, basophils and eosinophils) (Monticello et al., 1989): short-term (1- or 6-week) exposure at 7.38 mg/m^3^; “inflammatory cell” infiltration (Andersen et al., 2008): acute or short-term (1-d to 3-week) exposure at 7.38 mg/m^3^; miRNA changes associated with inflammation in rats and nonhuman primates (Rager et al., 2013; Rager et al., 2014): short-term (1- or 4- week, with some miRNA changes reversible with 1-week recovery) exposure at 2.46 mg/m^3^; in rats, 35 formaldehyde-responsive transcripts in the nose known to be related to immune cells indirectly indicated increases in granulocytes (i.e., eosinophil and neutrophil markers) and lymphocyte changes (Andersen et al., 2010): short-term (1-week, but not ≥4-week) exposure at ≥12.3 mg/m^3^. | | Moderate (↑ granulocytes: neutrophils and eosinophils); (Note: data on lymphocytes were indeterminate)
Nasal cellular inflammatory response | Low | Human: N/C in nasal lavage cell counts, but increased total protein (Priha et al., 2004): occupationally exposed (8-hr shift) 0.19 mg/m^3^; allergy-independent increased eosinophils, permeability (albumin index) and total protein in lavage (Pazdrak et al., 1993): acute (2-hr) exposure at 0.5 mg/m^3^; increased eosinophils, leukocytes, and permeability (albumin index) in lavage (Krakowiak et al., 1998): acute (2-hr) exposure at 0.5 mg/m^3^ (reversible); indirect evidence of eosinophil infiltration (increased markers: lysozyme and eosinophil cationic protein), but not neutrophils, at very low levels (Norback et al., 2000): <0.02 mg/m^3^ for unknown duration (likely ≥months) in schools. | Suggestive of cellular inflammation, particularly eosinophils, at 0.5 mg/m^3^ and indirect markers of eosinophil recruitment at lower levels in humans, following acute exposure; neutrophil inflammation observed at ≥6 mg/m^3^ in rats with short-term exposure. | Moderate (↑ granulocytes: neutrophils and eosinophils); (Note: data on lymphocytes were indeterminate)
Nasal cellular inflammatory response | Low | Animal: Neutrophil inflammation (Monteiro-Riviere and Popp, 1986): short-term exposure at ≥6 mg/m^3^. | | Moderate (↑ granulocytes: neutrophils and eosinophils); (Note: data on lymphocytes were indeterminate)
Modifications in the lower airways
↑ Lower respiratory tract (LRT) microvascular leakage | High or Medium | Human: None | Demonstrated increased leakage from acute exposure ≥6.15 mg/m^3^ in 1 study, which appears to be mediated by substance P. | Moderate (only examined in acute studies)
↑ Lower respiratory tract (LRT) microvascular leakage | High or Medium | Animal: Increased in rats (Ito et al., 1996): acute exposure at ≥6.15 mg/m^3^; note: inhibited at 18.45 mg/m^3^ by NK1 receptor antagonist (note: substance P binds NK1R), but not histamine or bradykinin antagonists. | Demonstrated increased leakage from acute exposure ≥6.15 mg/m^3^ in 1 study, which appears to be mediated by substance P. | Moderate (only examined in acute studies)
↑ Lower respiratory tract (LRT) microvascular leakage | Low | Human: None | One study suggests acute exposure as low as 1.23 mg/m^3^ induces microvascular leakage, although continued exposure appeared (at least in the near-term) to result in less leakage. | Moderate (only examined in acute studies)
↑ Lower respiratory tract (LRT) microvascular leakage | Low | Animal: Transiently increased in rats (Kimura et al., 2010): acute exposure at ≥1.23 mg/m^3^ (duration-independent); note: leakage blocked by inhibiting mast cells, but not blocking cyclooxygenases; indirect mechanistic data following injection of formalin into the trachea, causing leakage that appeared to be dependent on substance P release after stimulation of C-fiber afferents (Lundberg and Saria, 1983). | One study suggests acute exposure as low as 1.23 mg/m^3^ induces microvascular leakage, although continued exposure appeared (at least in the near-term) to result in less leakage. | Moderate (only examined in acute studies)
↑ Airway edema or other inflammatory structural changes | High or Medium | Human: None | Bronchial edema in one short-term study at 0.31 mg/m^3^. | Moderate (may require high exposure levels or allergen sensitization to elicit pronounced changes)
↑ Airway edema or other inflammatory structural changes | High or Medium | Animal: Increased edema in lung bronchi, but not alveoli, without signs of inflammation in lower airways in guinea pigs (Riedel et al., 1996): 5 d at 0.31 mg/m^3^, not at 0.16 mg/m^3^. | Bronchial edema in one short-term study at 0.31 mg/m^3^. | Moderate (may require high exposure levels or allergen sensitization to elicit pronounced changes)
↑ Airway edema or other inflammatory structural changes | Low | Human: None | Airway structural changes with allergen sensitization in two species (and, to a lesser extent, without sensitization) with short-term exposure at ≥3 mg/m^3^. | Moderate (may require high exposure levels or allergen sensitization to elicit pronounced changes)
↑ Airway edema or other inflammatory structural changes | Low | Animal: Airway structural changes consistent with inflammation (e.g., wall thickening; cell infiltration) in mice (Jung et al., 2007), some evidence for which was slight (Wu et al., 2013; Liu et al., 2011a), and in mice and rats sensitized with OVA (Wu et al., 2013; Qiao et al., 2009; Liu et al., 2011a), but not in nonsensitized rats (Qiao et al., 2009): all 2- to 3-week exposure at ≥3 mg/m^3^ [Note: most studied bronchial airways]. | Airway structural changes with allergen sensitization in two species (and, to a lesser extent, without sensitization) with short-term exposure at ≥3 mg/m^3^. | Moderate (may require high exposure levels or allergen sensitization to elicit pronounced changes)
LRT sensory nerve activation | High or Medium | Human: None | No evidence to evaluate | Slight (levels required for potential activation are unknown; may involve TRPA1 binding)
LRT sensory nerve activation | High or Medium | Animal: None | No evidence to evaluate | Slight (levels required for potential activation are unknown; may involve TRPA1 binding)
LRT sensory nerve activation | Low | Human: None | A single acute rat study and indirect evidence from potentially related exposures suggest that lower airway sensory nerve afferents may be activated, but the inhaled formaldehyde levels required for such potential activation have not been experimentally demonstrated. | Slight (levels required for potential activation are unknown; may involve TRPA1 binding)
LRT sensory nerve activation | Low | Animal: With acute exposure, dose-dependent increase in nerve currents and Cl^−^ release in intact rat trachea (Luo et al., 2013), with supporting evidence of substance P and NK receptor involvement. Indirectly, increased substance P and CGRP were observed in mouse lung tissue, both were amplified with OVA, and both were dependent on TRP activation (Wu et al., 2013): short-term exposure at 3 mg/m^3^. Note: the potential involvement of tracheobronchial reflexes, as is shown with direct LRT stimulation by irritants including cigarette smoke constituents and capsaicin (e.g., (Widdicombe, 1998)), may provide indirect support. | | Slight (levels required for potential activation are unknown; may involve TRPA1 binding)
↑ LRT oxidative stress | High or Medium | Human: Increased exhaled nitric oxide, a noninvasive marker of lower airway inflammation and oxidative stress, in healthy or asthmatic children (Franklin et al., 2000; Flamant-Hulin et al., 2010): unknown duration (likely months to years: classrooms or homes) at 0.04−0.06 mg/m^3^, but not in elderly nursing home patients at lower levels (Bentayeb et al., 2015) for unknown duration (likely months to years) at 0.005−0.01 mg/m^3^. | Increased biomarkers (indirect evidence) of oxidative stress in children at ≥0.04 mg/m^3^, but not in elderly individuals at ≤0.01 mg/m^3^ with prolonged (months−years) exposure, with indirect support from a subchronic rat study at >6 mg/m^3^. | Moderate (observed in children at low levels: ^~^0.04 mg/m^3^)
↑ LRT oxidative stress | High or Medium | Animal: Increased iron and zinc, indirect markers of potential oxidative stress, in lungs of male rats: 13 weeks at ≥6.15 mg/m^3^ (Ozen et al., 2003). | | Moderate (observed in children at low levels: ^~^0.04 mg/m^3^)
↑ LRT oxidative stress | Low | Human: None | Multiple studies in two species suggest elevated oxidative stress at ≥1 mg/m^3^ with short-term exposure. | Moderate (observed in children at low levels: ^~^0.04 mg/m^3^)
↑ LRT oxidative stress | Low | Animal: In mice: NO and NOS activity increased with 3 d exposure at 3 mg/m^3^ (Yan et al., 2005), GSH levels decreased with 3-week exposure at ≥0.5 mg/m^3^ (Ye et al., 2013b), and increased ROS or lipid peroxidation markers were observed with 3-week exposure at ≥1 mg/m^3^ (Ye et al., 2013b) or 2-week exposure at ≥6.15 mg/m^3^ (Jung et al., 2007), but decreased with acute exposure in one study (Matsuoka et al., 2010): 24-hr exposure at 0.12 mg/m^3^.; In rats: short-term studies at ≥12.3 mg/m^3^ demonstrated increased total oxidant levels and decreased total antioxidant level (Aydin et al., 2014), increased lipid peroxidation markers and protein oxidation markers (Sul et al., 2007), and decreased gamma-glutamyl transpeptidase (indirect evidence) (Dinsdale et al., 1993). | Multiple studies in two species suggest elevated oxidative stress at ≥1 mg/m^3^ with short-term exposure. | Moderate (observed in children at low levels: ^~^0.04 mg/m^3^)
↑ LRT eosinophils^b^; (see Appendix C.7 for discussion of LRT evidence on other cell types and soluble factors) | High or Medium | Human: None | Increased after subchronic exposure to 2.5 mg/m^3^ in mice coexposed to antigen. | Moderate (with short-term exposure at ≥0.5 mg/m^3^; note: moderate evidence for increases in total BAL cells or total white blood cells, under similar conditions; see Appendix C.7)
↑ LRT eosinophils^b^; (see Appendix C.7 for discussion of LRT evidence on other cell types and soluble factors) | High or Medium | Animal: ↑ in rats at 2.5 mg/m^3^ with coexposure to the antigen, ovalbumin (OVA) (Fujimaki et al., 2004b). | Increased after subchronic exposure to 2.5 mg/m^3^ in mice coexposed to antigen. | Moderate (with short-term exposure at ≥0.5 mg/m^3^; note: moderate evidence for increases in total BAL cells or total white blood cells, under similar conditions; see Appendix C.7)
↑ LRT eosinophils^b^; (see Appendix C.7 for discussion of LRT evidence on other cell types and soluble factors) | Low | Human: Two studies did not observe increases following acute exposure at 0.1 mg/m^3^ ((Casset et al., 2007); note: trend toward ↑) and 0.5 mg/m^3^ (Ezratty et al., 2007) with allergen coexposure (i.e., dust mite antigen; pollen). | Evidence of increases with short-term exposure (in general, at ≥0.5 mg/m^3^) in both rats and mice; the data suggest that changes may not occur after acute exposure. | Moderate (with short-term exposure at ≥0.5 mg/m^3^; note: moderate evidence for increases in total BAL cells or total white blood cells, under similar conditions; see Appendix C.7)
↑ LRT eosinophils^b^; (see Appendix C.7 for discussion of LRT evidence on other cell types and soluble factors) | Low | Animal: ↑ in four short-term studies of mice in the absence of antigen [12.3 mg/m^3^; (Jung et al., 2007)], with antigen (>^~^12.3 mg/m^3^ with house dust mite antigen; (Sadakane et al., 2002)^a^), or both with and without antigen (at 0.5−3 mg/m^3^ ± OVA (Liu et al., 2011a), and at 3 mg/m^3^ ± OVA (Wu et al., 2013)); ↑ in one short-term rat study at 0.5−3.1 mg/m^3^ with OVA antigen (Qiao et al., 2009) One acute rat study did not observe effects at 6.2 mg/m^3^ without antigen (Kimura et al., 2010). | Evidence of increases with short-term exposure (in general, at ≥0.5 mg/m^3^) in both rats and mice; the data suggest that changes may not occur after acute exposure. | Moderate (with short-term exposure at ≥0.5 mg/m^3^; note: moderate evidence for increases in total BAL cells or total white blood cells, under similar conditions; see Appendix C.7)

a Reported as 0.5% formaldehyde solution; concentration assumed to be >12.3 mg/m^3^ (Sadakane et al., 2002).

b There was also slight evidence for increases in eosinophil attractant and adhesion factors (see Appendix C.7).

##### Summary of Inferences Regarding Mode of Action

Although a definitive MOA has not been fully identified, several contributing mechanistic events interpreted with moderate or robust evidence appear to impact pulmonary function and, taken together, these data provide support for the biological plausibility of formaldehyde exposure-induced decreases in pulmonary function. However, important gaps in understanding of the MOA exist and some of the most biologically relevant mechanistic findings have not been examined at lower formaldehyde concentrations (e.g., < 1 mg/m^3^). In addition, several important mechanistic events have only been examined in longer-term, or conversely short-term studies, complicating interpretations of duration-dependence. Thus, notable uncertainties exist.

#### Evidence Integration Summary

Measures of pre-shift FEV1, FVC, FEV1/FVC, and expiratory flow rates were generally lower in highly exposed occupational groups compared to their nonexposed or lesser-exposed comparison groups. While the direction of the associations was generally consistent, some effect estimates were imprecise. The differences may be a result of individual variability, lower sensitivity in some studies to detect small mean differences or changes, or random variation. Another source of variation may be incomplete control for confounders (e.g., smoking, dust, other pollutant exposure), although some studies did adjust for these factors and still observed an independent association with formaldehyde, and associations were found among groups in different exposure settings. Evidence from two of three panel studies, both conducted by one investigator group, provides limited support that formaldehyde exposure during anatomy labs results in pulmonary function declines over several weeks duration.

Demonstrated exposure-response trends were observed in four high or medium confidence studies (Wallner et al., 2012; Malaka and Kodama, 1990; Krzyzanowski et al., 1990; Kriebel et al., 2001). An increase in pulmonary function deficits with increasing exposure was reported by a study of woodworkers with area formaldehyde levels ranging from 0.27−4.28 mg/m^3^ (Malaka and Kodama, 1990). Dose dependent decreases in pulmonary function were observed among adults smokers and children who lived in mobile homes with average formaldehyde concentrations of 0.032 mg/m^3^ and a maximum of 0.172 mg/m^3^ (Krzyzanowski et al., 1990) and also by a study of pollutant exposures among school children (Wallner et al., 2012). Dose-dependent decreases in PEF also were observed among anatomy students exposed to an average formaldehyde concentration of 1.35 mg/m^3^ with peak concentrations of 13.4 mg/m^3^ (Kriebel et al., 2001).

Smoking, health status, and lifestage may increase sensitivity to inhaled formaldehyde. The limited number of population-based studies evaluating lower exposure levels indicates that while, in general, no associations were observed among adults as a whole, declines were reported for smokers and the elderly living in nursing homes. The study with the strongest design and methods found an association with declines in PEFR among adult smokers and increasing average formaldehyde concentration between 0.049 and 0.172 mg/m^3^ (Krzyzanowski et al., 1990). In this large, population-based sample, the investigators also observed a linear relationship between increased formaldehyde exposure and decreased peak expiratory flow rate (PEFR) among children exposed to average concentrations of 0.032 mg/m^3^ (26 ppb), and a stronger response was observed among children with asthma. The stability of average exposure concentrations between sampling periods, some separated by weeks, was confirmed by the investigators, thus the high quality exposure assessment addressed the etiologically relevant time window for the evaluation of associations with ongoing pulmonary function status. The analyses controlled for other exposures including smoking status, environmental tobacco smoke and NO_2_. This finding is supported by declines in some of the pulmonary function measures in a medium confidence study in schools (Wallner et al., 2012).

While there were very few studies in humans that inform potential biological mechanisms (i.e., several studies indirectly support inflammatory changes in the LRT), experimental evidence primarily from animal studies provides robust or moderate evidence of mechanistic changes that can be plausibly associated with effects on pulmonary function, including increases in airway eosinophils and other inflammatory airway changes that appear to be at least partially dependent on indirect activation of sensory nerve endings in the LRT. Taken together, the data provide what is likely to be an incomplete mechanism explaining how formaldehyde exposure might result in decreased pulmonary function. Uncertainties remain regarding the initial cellular or tissue modifications that ultimately lead to the observed mechanistic changes in the lower airways, and it is unclear whether certain events would be triggered with chronic, low-level exposure.

Overall, based on moderate human evidence from observational epidemiology studies, with corresponding slight evidence for an effect in animals based on mechanistic studies supporting biological plausibility, the evidence indicates that long-term inhalation of formaldehyde likely causes decreased pulmonary function in humans given sufficient exposure conditions. The primary support for this conclusion includes a study of children and adults in a residential setting (mean, 0.03 mg/m^3^, maximum 0.17 mg/m^3^) and several studies of workers with long-term exposure to >0.2 mg/m^3^ (see Table 3-10).

Table 3-10 Evidence integration summary for effects of long-term (months to years) formaldehyde inhalation on pulmonary function

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis Judgment | Hazard determination
Human | Consistency and Study Confidence | - Numerous high and medium confidence studies show a pattern of lower mean pulmonary function in formaldehyde-exposed occupational groups compared to referent groups across a variety of exposure settings and countries, plus longitudinal declines in two occupational populations and a panel study of medical students.; - A large, population-based study observed a linear relationship between increased formaldehyde exposure and decreased peak expiratory flow rate (PEFR) among children overall, with a stronger response among children with asthma. A study among school children also found deficits using a different measure. | - Null or equivocal associations were identified for some studies; these studies had limitations that may have contributed to lower sensitivity.; - Some inconsistencies across studies were noted for specific PEF measures; possible explanations include random variation and low study sensitivity. | Moderate; Based on consistency across exposure settings (residential, occupational) and study designs (cross-sectional, longitudinal), multiple observations of dose-dependent reductions and greater sensitivity among susceptible groups (children, asthmatics, adult smokers, elderly). Confidence is moderated by less consistent observations for individual pulmonary function measures across studies. | The evidence indicates that long-term inhalation of formaldehyde likely causes decreased pulmonary function in humans, given sufficient exposure conditions^a^.; Primarily based on moderate human evidence from a study of children and adults in a residential setting (mean, 0.03 mg/m^3^, maximum 0.17mg/m^3^) and numerous studies of workers with long-term exposure to >0.2 mg/m^3^ formaldehyde.; Potential Susceptibilities: Variation in sensitivity is anticipated to depend on age and respiratory health (including smoking status), with the potential for children (particularly children with asthma) to be more sensitive.
Human | Strength and Precision | - One high and two medium confidence studies in residential and school populations indicate that susceptible individuals may experience reduced pulmonary function at lower average concentrations (<0.05 mg/m^3^). | - Some of the observed decreases in pulmonary function were small in magnitude (< 1−2%).; - Some of the differences between exposed and their referent groups in occupational studies were imprecise.
Human | Dose-Response | - Concentration-related decrements in pulmonary function from four high and medium confidence adjusted analyses indicate an independent association for formaldehyde exposure.
Human | Coherence | N/A
Human | Biological Plausibility | - Some indirectly supportive mechanistic information from well-conducted human studies exists related to increased lower airway oxidative stress following exposures likely to span months to years.
Animal | Animal studies of pulmonary function endpoints were not formally evaluated (see Section 2.2.3). | | | Slight; Based on mode of action evidence from experimental animal studies.
Animal | Biological Plausibility | - Understanding of the partial MOA likely to underly the development of pulmonary function decrements following formaldehyde inhalation is primarily based on experimental studies in animals. Although uncertainties remain, this strong mechanistic evidence alone is considered to support an animal evidence synthesis judgment stronger than indeterminate. | | Slight; Based on mode of action evidence from experimental animal studies.
Other inferences | - Relevance to humans: The primary effect of interest was observed in humans (moderate evidence).; - MOA: Not established, but likely to involve airway eosinophil increases and stimulation of airway sensory nerve endings. Specifically, robust and moderate evidence for several mechanistic events, primarily from experimental animal studies, provides support for inflammatory changes in the lower airways, including eosinophil increases, which appear to be at least partially dependent on indirect stimulation of sensory nerve endings. While evidence exists for some changes in the range of 0.3−0.5 mg/m^3^ with exposure for several weeks, some potential associations in the identified, incomplete MOA pathway have only been tested at higher (i.e., >1 mg/m^3^) levels and with shorter-term exposures. This partial MOA is assumed to be relevant to humans based on similarities in systems mediating the identified MOA across species and some supportive findings for lower airway mechanistic changes in exposed humans.

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

### 3.2.3 Immune-mediated Conditions, Focusing on Allergies and Asthma

This section examines the evidence pertaining to the effect of formaldehyde exposure on immune-mediated responses, primarily in the respiratory system, focusing on allergy-related conditions (e.g., rhinitis, rhinoconjunctivitis, eczema), and asthma; sensitization related to dermal exposure is not a focus of this review. Lower respiratory tract conditions in infants and children up to 3 years in age, in particular wheezing episodes, are also examined as a separate endpoint. Experimental animal studies were ultimately concluded to be unsuitable models (i.e., indeterminate) for evaluating allergy-related conditions and asthma as apical outcomes (see discussion in Immune-mediated Conditions, Focusing on Allergies and Asthma, in Animal Studies). Studies examining respiratory immune function (i.e., the ability to respond to infection) are discussed within the wider context of potential mechanistic changes that might explain respiratory health hazards (see Appendix C.7 and discussion below in Evidence on MOA), rather than as an independent health hazard to be evaluated. The mechanistic studies considered most relevant to these health outcomes provided biological support for the immune-mediated conditions observed in humans, although complete and definitive MOAs could not be established and several changes thought to be important to the development or progression of asthma, in particular, were not identified. The few available studies on developmental immunotoxicity in animals (hypersensitivity studies) were indeterminate in regard to the information necessary to draw conclusions.

The general population studies in children (ages >= 5 years) and adults (ages 18 to 65 years) provided evidence of an association between formaldehyde exposure and prevalence of rhinitis, or rhinoconjunctivitis, with a relative risk of approximately 1.2 for formaldehyde exposures of around 0.04−0.06 mg/m^3^. Although the effect size was small, these are relatively common conditions and could result in a large impact in the population. A stronger association (two-fold risk) was seen in the only study of eczema in adults. Eczema, while not indicative of an allergic respiratory response, is often associated with other allergic disorders, including those affecting the respiratory system [e.g., allergic rhinitis; (Weidinger and Novak, 2016a, b)], and it appears that some inhaled allergens may have the potential to exacerbate this condition (Morren et al., 1994; Mendell et al., 2011). The available general population studies also provided evidence of an association between formaldehyde exposure and the prevalence of current asthma, typically as determined by symptoms or medication use in the past 12 months, in studies with some exposures above 0.05 mg/m^3^, but associations were not seen in settings with exposures below 0.05 mg/m^3^. For the allergy-related outcomes and asthma, the study designs and outcome classification used in the high and medium confidence studies were considered to be appropriate by the two expert panels consulted by the EPA. The two studies examining asthma control or severity among children with asthma suggest associations may be seen at lower exposures (e.g., 0.04 mg/m^3^) in this potentially susceptible population. Relatively strong associations were seen in studies examining prevalence of current asthma in relation to formaldehyde exposure in occupational settings (exposures above 0.10 mg/m^3^). The mechanistic evidence supports that formaldehyde exposure can induce bronchoconstriction and lead to the development of hyperresponsive airways,^18^ particularly with allergen sensitization. These heightened responses may be due to a combination of potentially progressive changes, including neurogenic increases in tachykinins and eosinophil recruitment and activation in the lung. The mechanistic studies also provided consistent evidence that formaldehyde may stimulate a number of immunological and neurological processes related to asthmatic responses; however, a molecular understanding of how formaldehyde exposure favors asthmatic T-helper 2 (T_H_2) responses has not been experimentally established.

Overall, based primarily on a moderate level of human evidence supporting an association from the available epidemiological studies, with corresponding slight evidence for an effect in animals based on mechanistic studies in animals supporting biological plausibility, the evidence indicates that inhalation of formaldehyde likely causes an increased risk of prevalent allergic conditions and prevalent asthma symptoms, as well as decreased control of asthma symptoms, given sufficient exposure conditions. The primary basis for this conclusion involves studies of occupational settings (>0.1 mg/m^3^) and population studies where formaldehyde concentrations measured in schools and homes averaged between 0.05 and <0.1 mg/m^3^.

#### Human Studies

In the following sections, the evidence regarding allergic conditions (symptoms, skin prick tests) from general population studies is discussed by age category (i.e., children, adults). For asthma, general population studies of asthma prevalence and degree of control among children and adults are discussed by exposure setting (general population, occupational). In addition, responses among asthmatics to acute exposure are described (controlled human exposure studies), followed by other respiratory conditions in infants and toddlers, and a discussion of factors that may increase susceptibility. As described in Section 2.3.4, these studies were evaluated and classified by confidence (see Appendix B.3.4 for documentation). The studies are summarized in tables for these outcomes that are ordered by age group, confidence in study results, and publication year.

##### Allergic conditions

The set of seven high and medium confidence general population studies of allergy-related conditions were conducted in school children in France (Annesi-Maesano et al., 2012), Romania (Neamtiu et al., 2019), Malaysia (Norbäck et al., 2017), Korea (Yon et al., 2019), and China Huang et al. (2017) and in adults in France (Billionnet et al., 2011) and Japan (Matsunaga et al., 2008). These studies provide evidence that formaldehyde exposure around 0.04 mg/m^3^ and above is associated with an increased prevalence of rhinitis or rhinoconjunctivitis in children, with relative risks of approximately 1.2 (see Figure 3-8, Table 3-11). Two studies in children did not observe an association with rhinitis at lower exposure levels (0.004–0. 027 mg/m^3^) (Norbäck et al., 2017); Huang et al. (2017). The point estimates of the relative risks in two studies of rhinitis in adults covering a higher exposure range were also around 1.2, but these estimates were highly imprecise and so cannot be interpreted as strong support for an association (or for no association) in this older population (Matsunaga et al., 2008; Billionnet et al., 2011) (see Figure 3-8). Annesi-Maesano et al. (2012) examined more than two exposure groups in relation to rhinoconjunctivitis risk in children and observed the highest relative risk in the highest exposure group compared to the referent group, with weaker or no associations seen in the lower exposure categories; no other pollutants (e.g., NO_X_, PM_2.5_, acetaldehyde, acrolein, ETS) were associated with rhinoconjunctivitis in this study. Another school-based study reported associations with the prevalence of rhinitis (RR 1.207, 95% CI: 1.02,1.44) and with severity of rhinitis (RR 1.28, 95% CI: 1.07, 1.54) per 0.01 mg/m3 increase in formaldehyde at levels up to 0.066 mg/m^3^ (Yon et al., 2019). A stronger association (RR 2.25, 95% CI: 1.01, 5.01) was seen in the only study of eczema in adults at exposures of 0.058 - 0.161 mg/m^3^ compared to < 0.058 (midpoint approximately 0.033) mg/m^3^ (Matsunaga et al., 2008). Neamtiu et al. observed a 3-fold increased risk (RR 3.23, 95% CI: 1.31, 8.00) for a combination of symptoms relating to eye, nose, and skin in children exposed to formaldehyde (Neamtiu et al., 2019). A relative risk of 1.4 for formaldehyde exposures above approximately 0.035 mg/m^3^ and atopy based on skin prick tests was also seen in a study in children (Garrett et al., 1999), but not in the study by Palczynski et al. (1999) (see Table 3-12). Both of these were classified as medium confidence with respect to the results in children. The exposure range examined in Garrett et al. (1999) is wider than that in Palczynski et al. (1999), and the exposure measurement protocol (four 1-day samples in different seasons) was an additional strength of the study by Garrett et al. (1999). This study also reported associations between formaldehyde exposure and both wheal size and the number of positive skin prick tests (from a mean of approximately 1.5 in the lowest to 4.0 in the highest category of exposure). A limitation of the skin prick test studies was the uncertainty regarding the congruence between the exposure measure and the exposure during the relevant time window with respect to development of sensitization; EPA considered this to be of particular importance with respect to studies of skin prick tests in adults. In particular, all of the residences in the study by Palczynski et al. (1999) had been built 10 years prior to enrollment in the study, and sensitization may have occurred years before the exposure assessment, possibly when exposure levels were higher. A similar concern was raised for Garrett et al. (1999), as the authors did not report the age of the housing stock for participants and 74% of the children had lived in their homes at least 5 years.

Results from the two occupational studies were mixed (see Table 3-13). Both are considered low confidence based primarily on limitations of the outcome ascertainment used in these studies.

Because of the limitations noted above with respect to interpretation of skin prick tests, EPA has higher confidence in the studies of allergy-related conditions. Consistent results were observed for various symptoms or combinations of symptoms across this set of studies in children at exposures around 0.05 mg/m^3^ and above, and in the only study of eczema in adults comprising diverse populations. The pattern of exposure-response seen in the studies with sufficient sample size and range of exposure to examine these patterns suggests that formaldehyde exposure at levels seen in the general population studies can enhance the immune hypersensitivity response to allergens. The studies of allergy-related conditions are summarized in Figure 3-8.

Figure 3-8 Relative risk estimates for prevalence of allergy-related conditions in children and adults in relation to formaldehyde in residential and school settings

Results are depicted for rhinitis (circles), rhinoconjunctivitis (diamonds), eczema (triangles) and symptom combinations (squares). High and medium confidence studies are included in the figure. Open symbols are for studies in children (panel a); closed symbols are for studies in adults (panel b). NS = no quantitative results were available; however, Norback et al. (2017) reported no association. Mg/m^3^ = for studies using categorical analysis, is approximate midpoint of formaldehyde levels calculated for the group being compared to the referent group. For studies using continuous analysis, different measures were available for the different studies; the 75^th^ percentile was used for Huang et al. 2017; the mean + 1 SD was used for Yon et al. 2019; and the maximum value was used for Norback et al. 2017. Low, mid, and high refer to the relative formaldehyde levels; RR = relative risk. in studies with categorical analysis.

Table 3-11 History of allergy-related conditions in relation to formaldehyde exposure, by age group

Study and design^a^ | Results
Study and design^a^ | Nasal | | | | Dermatologic
Children
Annesi-Maesano et al. (2012); (France); Design: Prevalence study, n = 6,683, ages 9−10 years, participation rate 69%. Sampling from 108 schools, all classes of specified grade level per school.; Exposure: 5-day samples in classrooms. Median (75^th^ percentile) 0.027 (0.034) mg/m^3^; maximum 0.055 mg/m^3^; (estimated from Figure 1 in paper).; Outcome: Based on ISAAC questionnaire, parent report, sneezing and runny nose, with itchy eyes, without a cold, in past 12 months.; Evaluation ^a^ :; High confidence | Rhinoconjunctivitis prevalence 11.8%, OR (95% CI) (adjusted) | | | | Not examined
| ≤0.0191 mg/m^3^ | | 1.0 (referent) | | Not examined
| >0.0191−0.0284 | | 1.11 (0.94, 1.37) | | Not examined
| >0.0284−^~^0.055 | | 1.19 (1.03, 1.39) | | Not examined
| (Confidence intervals estimated from Figure 3 in paper) | | | | Not examined
| Adjusted for age, gender, passive smoking, maternal and paternal history of asthma and allergic diseases. | | | | Not examined
Yon et al. (2019); (Seongnam City, Korea); Design: Prevalence study, n = 427 school children recruited from 22 randomly selected classrooms at 11 elementary schools; 68.9% participation rate, ages 10–12 years.; Exposure: Formaldehyde sampling in each classroom using monitors with pumps during the 1st and 2nd half of the school year.; Mean 0.027 ± 0.0077 mg/m^3^; as high as 0.06 mg/m^3^ in some classrooms. Duration and sampling methods were not described.; Outcome: Rhinitis definition: presence of characteristic symptoms and /or signs during the previous 12 months using ISAAC questionnaire. Rhinitis severity: low, moderate, severe, using Allergic Rhinitis and Its Impact in Asthma guidelines.; Evaluation:; Medium confidence; Uncertainty regarding validation of ISAAC in this population; uncertainty regarding exposure measurement period and other protocol details. | Rhinitis prevalence: 57.6%, n = 246; OR (95% CI) per 0.010 mg/m^3^; 1.21 (1.02, 1.44) adjusted for age, sex, environmental tobacco smoke exposure, and physician-diagnosed allergic rhinitis in parents.
| Rhinitis severity
| | n | OR (95% CI) per 0.010 mg/m^3^
| Control | 181 | Reference
| Mild | 44 | 1.21 (0.91, 1.60)
| Moderate/Severe | 202 | 1.28 (1.07, 1.54)
| p _trend_ = 0.011
| [Results represented by authors were in units of per 1 µg/m^3^ increase; EPA converted these to per 0.01 mg/m^3^ increase to facilitate comparison with other studies]
Neamtiu et al. (2019) (Romania); Design: Prevalence study; n = 281 89.7% participation rate.; Sampling from five primary schools in one county, 3 classrooms per school.; Exposure: 5-day samples in each classroom.; Median (75th percentile) 0.035 (0.045) mg/m^3^, maximum = 0.066 mg/m^3^.; Outcome: Allergy-like symptoms in the past week based on ISAAC questionnaire, as skin conditions (e.g., rash, itch, eczema), eye disorders (e.g., red, dry, swollen, itching, or burning eyes, or sensation of “sand in the eyes,” and rhinitis symptoms (e.g., itching nose, sneezes, and/or stuffy or blocked nose.; Evaluation ^a^; Medium confidence; Outcome definition for allergy-like symptoms using ISAAC questionnaire included combined symptoms of rhinitis (nose), eye, and skin conditions (rash, itch, and eczema), which could mask an effect in one of these categories. Skin condition question not specific for eczema. | Allergy-like symptoms (eyes, nose and skin); OR (95% CI), above compared to below median (0.035 mg/m^3^):; 3.23 (1.31, 8.00).; Logistic regression model adjusted for age, gender, NO_2_, CO, CO_2_, temperature, relative humidity, ventilation rate, and tobacco smoke exposure for the past week.
Norbäck et al. (2017) (Malaysia); Design: Prevalence study, n = 462 randomly selected children recruited from 8 randomly selected schools (15 students in each of 4 randomly selected classes per school). 96% participation rate. Mean age 14 years (range 14–16 years), 48% male.; Exposure: Formaldehyde sampled continuously over 7 days in each classroom using diffusion samplers. Samplers placed 2 meters above floor, methods described.; Mean concentrations formaldehyde indoor 0.0042 mg/m^3^(SD not reported), max 0.018 mg/m^3^, 100% samples above the detection limit. Outside 0.005 mg/m^3^, max 0.0060 mg/m^3^, 100% samples above the detection limit.; Outcome: Rhinitis defined by two questions combined regarding nasal catarrh or nasal congestion in standardized questionnaire. Cases defined by reporting symptoms weekly over a 3-month period.; Evaluation^a^:; Medium confidence; Results for rhinitis were reported as “not statistically significant” without providing quantitative effect estimates. Very low indoor formaldehyde concentrations. | Rhinitis, weekly symptoms during previous 3 months.; Prevalence 18.8%.; No association with formaldehyde in initial model; quantitative results were not reported.; Initial stepwise multiple logistic regression model included indoor exposures (CO_2_, NO_2_, formaldehyde and VOC), personal factors (sex, race, current smoking, atopy, parental asthma/allergy) and home environment factors (ETS, dampness/mold, recent indoor painting), total amount of dust in the classroom and the concentration of endotoxin, and ergosterol in vacuumed dust.
Huang et al. (2017); (Shanghai, China); Design: Case-control study, n = 409 children, aged 5–10 years, who were participants in a previous cross-sectional study (2011–2012) selected from 88 kindergartens located in 6 Shanghai districts. Eligible children lived in homes not renovated in prior two years and agreed to home inspection during March 2013-December 2014.; Exposure: Formaldehyde sampling in child’s bedroom, 24 hours, in breathing zone (detection range: 0.012-0.08 mg/m^3^). Mean (± SD) concentration (mg/m^3^), 24-hr 0.0215 ± 0.0130; 75th percentile 0.0275 mg/m^3^; Range 0.006–0.060 mg/m^3^, 3 homes above.; Outcome: Rhinitis and eczema in past 12 months using selected questions from translated ISAAC questionnaire.; Evaluation^a^:; Rhinitis:; Medium confidence; Participation rate unclear, and potentially differential with respect to exposure and disease status.; Eczema:; Low confidence; See above, and uncertainty regarding validation of truncated version of ISAAC questionnaire for eczema in this population. | Current rhinitis 41.4%; OR (95% CI) per IQR (0.0152 mg/m^3^); 0.72 (0.47, 1.10).; Logistic regression adjusted for age, sex, family history of atopy, family annual income, household (ETS), early and current household dampness-related exposures, early antibiotics exposure, early home decoration, and the inspection season.
| Current eczema 13.4%; OR (95% CI) per IQR (15.2 µg/m^3^); 0.75 (0.41, 1.39).
Isa et al. (2020); (Malaysia); Design: Prevalence study; n = 470, participation rate not reported. 8 randomly selected schools (4 urban, 4 suburban), randomly selected students from 4 classes (Form two, aged 14 years) during August-November 2018 & February 2019.; Exposure: One-hour samples in four classes during class session.; Median (IQR) Urban: 0.0132 (0.0093) mg/m^3^, Suburban: 0.0031 (0.0052) mg/m^3^ (reported as mg/m^3^ but likely µg/m^3^).; Outcome: Allergy information and symptoms within defined period using ECRHS and ISAAC questionnaires. Allergic symptoms in last 12 months: rhinitis, skin allergy.; Evaluation:; Low confidence; Uncertainty in exposure concentrations and distribution given short sampling duration; very low concentrations in half the schools. | Rhinitis in last 12 months 55.5%; OR (95% CI) per 10 units formaldehyde (reported as mg/m^3^ but likely µg/m^3^).; 1.10 (1.03, 1.17); Adjusted for atopy, parental asthma/allergy, and NO_2_. | | | | Skin allergy in last 12 months 14.5%; OR (95% CI) per 10 units formaldehyde (reported as mg/m^3^ but likely µg/m^3^).; 2.41 (0.96, 6.07); Adjusted for atopy, sex, doctor’s diagnosed asthma, parental asthma/allergy and urban/suburban location; not modeled further because this result was considered not statistically significant, Stronger association seen with NO_2_ and PM_10_ but no model presented with formaldehyde and these other exposures.
Hsu et al. (2012) (Taiwan); Design: Case-control study, n = 48 allergic rhinitis cases, 36 eczema cases 42 controls, recruited through kindergartens and day care centers, ages 3−9 years at enrollment. Participation rate (clinic exam and home measures) approximately 5% of potential cases and controls (but differential at various steps).; Exposure: 2-hour household sample (probably bedroom; converted from ppb); Median (25th, 75th percentile): Controls 0.017 (0.005, 0.030) mg/m^3^; Outcome: Initial screening through parent report of history (ages 2−6) with confirmation (1−3 years later) by clinical examination.; Evaluation^a^:; Low confidence; Low and differential (at various steps) participation rate. Short exposure sampling period and no information on protocol. | Allergic rhinitis; Formaldehyde concentrations lower in cases than in controls:; (n) Median (25th, 75th percentile) mg/m^3^; Controls (42) 0.017 (0.005, 0.030); Allergic rhinitis (48) 0.005 (0.005, 0.020); (p = 0.02); Mann-Whitney nonparametric test | | | | Eczema; Formaldehyde concentrations lower in cases than in controls:; (n) Median (25th, 75th percentile) mg/m^3^; Controls (42) 0.017 (0.005, 0.030); Eczema (36) 0.006 (0.005, 0.018); (p = 0.07); Mann-Whitney nonparametric test
Choi et al. (2009) (Korea); Design: Case-control study, n = 50 atopic dermatitis cases, 28 controls, recruited through university outpatient clinic; recruitment procedures not described. Mean age (SD) 15.4 years (3.4) and 16.2 years (4.1) in atopic dermatitis cases and controls, respectively. Housing age and type: cases 58% <3 years old and 72% apartments; controls 29% <3 years old and 50% apartments. Location: 44 and 21% near road for cases and controls, respectively.; Exposure: Household sample (sampling period not reported, but closed windows and use of duplicates).; Geometric mean, 25th, and 75th percentiles in controls: 0.043 (0.024, 0.115) mg/m^3^. 92% above LOD.; Outcome: Atopic dermatitis based on medical history, skin prick test and IgE (criteria not provided).; Evaluation^a^:; Low confidence; Selection and recruitment process not reported; sampling period not reported and specific criteria for case definition not reported; potential confounders not addressed (age and type of housing and location differed between cases and controls, as measure of socioeconomic status). Limited analysis. | Not examined | | | | Formaldehyde levels (mg/m^3^):
| Not examined | | | | | Geometric mean | 75th percentile
| Not examined | | | | Cases | 0.100 | 0.220
| Not examined | | | | Controls | 0.043 | 0.115
| Not examined | | | | p < 0.01
Smedje and Norback (2001); (Sweden); Design: Prospective (incidence) nested case-control study, children, 1,258 without asthma at baseline, 88 incident cases of pollen allergy and 50 incident cases of pet allergy in 4-year follow-up; 78% participation in follow-up, mean age 10.3 years at baseline. School-based sample; 1st, 4th, and 7th grades.; Exposure: Two 4-hour samples in 2−5 classrooms per school; measured in 1993 (n = 98) and 1995 (n = 101).; mean 0.008 mg/m^3^, geometric mean 0.004 mg/m^3^ (min, max) (<0.005, 0.072) mg/m^3^, 54% of 1993 samples and 24% of 1995 samples below detection limit (0.005 mg/m^3^); median among those above detection limit = 0.010 mg/m^3^. Individual student values based on average of 1993 and 1995 classrooms (<0.005 to 0.042 mg/m^3^).; Outcome: Parent report, hay fever/pollen allergy or pet dander allergy.; Evaluation^a^:; Low confidence; Exposure measures in only 2 of the 4 years and 2/3 of the students left the school more than a year before follow-up; uncertainty about distribution; relatively high percentage <LOD. Confounding by other exposures not fully addressed but pattern of results differed among the exposures examined.; Related References: Smedje et al. (1997). | Allergies (incidence); RR (95% CI) per 0.010 mg/m^3^, | | | | Not examined
| Pollen allergy: | | 1.3 (0.95, 1.7) | | Not examined
| Pet allergy: | | 1.1 (0.7, 1.7) | | Not examined
| Adjusted for sex, age, history of atopy, smoking. | | | | Not examined
Adults
Billionnet et al. (2011) (France); Design: Prevalence study, n = 916 adults from 490 dwellings (drawn from nationally representative sample; 13.6% participation rate), median age 44 (15−89); 48% men.; Exposure: 1-week sample in bedroom; Median, 75th percentile (minimum, maximum) 0.0194, 0.028 (0.013, 0.0863) mg/m^3^.; Outcome: ISAAC questionnaire; wheezing, running or blocked nose without cold or respiratory infection, in past 12 months.; Evaluation^a^:; Medium confidence; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. | Rhinitis prevalence 38.3%; OR (95% CI), above vs. below 75th percentile:; 0.028 to 0.0863 vs. <0.028 mg/m^3^; 1.14 (0.8, 1.6); Adjusted for age, gender, smoking, education, relative humidity, time of survey, pets, mold, outdoor pollution measures. | | | | Not examined
Matsunaga et al. (2008) (Osaka, Japan); Design: Prevalence study. Adults, n = 998 women, median 17th week of pregnancy, median age ^~^30. Recruited through obstetric clinics and public health nurses.; Participation rate 17% of pregnant women in the area.; Exposure: 24-hour personal sample (converted from ppb).; Median 0.030, maximum; 0.161 mg/m^3^.; Cutpoints based on 30th, 60th, and 90th percentiles (<0.022, 0.022−0.033, 0.034−0.57, and ≥0.058 mg/m^3^).; Outcome: Self-report, treatment for allergic rhinitis or atopic eczema in past 12 months.; Evaluation^a^:; Medium confidence; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. Some uncertainty pertaining to sensitivity and specificity of outcome assessment. | Allergic rhinitis (14.0% prevalence) | | | | Atopic eczema (5.7% prevalence)
| mg/m^3^ | n | OR | (95% CI) | mg/m^3^ | n | OR | (95% CI)
| <0.022 | 298 | 1.0 | (referent) | <0.022 | 298 | 1.0 | (referent)
| 0.022−0.033 | 299 | 1.06 | (0.65, 1.73) | 0.022−0.033 | 299 | 1.03 | (0.47, 2.29)
| 0.034−0.057 | 301 | 0.85 | (0.51, 1.40) | 0.034−0.057 | 301 | 1.11 | (0.50, 2.42)
| 0.058−0.161 | 100 | 1.17 | (0.60, 2.28) | 0.058−0.161 | 100 | 2.36 | (0.92, 6.09)
| (trend p-value) | | | (0.91) | (trend p-value) | | | (0.08)
| 0.058−0.161 vs. <0.058 | | 1.22 | (0.68, 2.20) | 0.058−0.161 vs. <0.058 | | 2.25 | (1.01, 5.01)
| | | | | per 0.0123 mg/m^3^ | | 1.16 | (0.99, 1.35)
| Adjusted for age, gestation, parity, family history (of asthma, atopic eczema, allergic rhinitis), smoking status, current passive smoking at home and work, mold in kitchen, indoor domestic pets, dust mite antigen level, family income, education, and season.; (Midpoint of highest quartile estimated as 0.07 mg/m^3^ based on personal communication (Matsunaga, 2012)) | | | | Adjusted for same factors as allergic rhinitis analysis.; Additional analyses examined effect modification by family history of asthma, atopic eczema, or allergic rhinitis, see Figure 3-11 in this report.; (Midpoint of highest quartile estimated as 0.07 mg/m^3^ based on personal communication (Matsunaga, 2012)).

Within each age group, organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

Abbreviations: ISAAC = International study of Asthma and Allergies in Children; ECRHS = European Community Respiratory Health Survey.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4).

Table 3-12 Skin prick tests in relation to formaldehyde exposure, by age group

Study and design | Results
Children
Garrett et al. (1999) (Australia); Design: Prevalence study, n = 145 (57 asthma cases, 88 controls; combined for this analysis; some cases and controls from same household; three excluded for total n = 145), ages 7−14 (mean 10.2) years.; Exposure: 4-day (one per season) measures in home (bedroom, living room, kitchens, outdoors). 74% of the children had lived in the house for at least 5 years; 34% for entire life.; Median (maximum) 0.0158 (0.139) mg/m^3^.; Outcome: Atopy based on skin prick tests to 12 allergens (cat, dog, grass mix #7, Bermuda grass, house dust, two dust mite, five fungi).; Evaluation^a^:; Medium confidence (↓); Uncertainty about effect of recruitment process and ability to fully address household correlation of cases and controls; could result in attenuated effect estimate. | Atopy prevalence: 88/145 = 0.61
| Exposure (mg/m^3^) | N | Proportion with atopy
| <0.020 | 30 | 0.33
| 0.020−0.050 | 75 | 0.64
| > 0.050−0.139 | 40 | 0.75
| (trend p-value) | | (<0.001)
| per 0.020 mg/m^3^ increase OR 1.42 (0.99, 2.04)
| Odds ratio, adjusted for parental asthma history, sex; other factors examined (passive smoke, pets, indoor NO_2_, fungal spores, house dust mite allergens). (Similar trend seen based on bedroom measure: prevalence 0.50, 0.59, 0.74, trend p = 0.06.)
| Exposure (mg/m^3^) | N | Number of allergens^a^ | Wheal size^a^
| <0.020 | 30 | 1.3 | 0.5
| 0.020−0.050 | 75 | 3.4 | 1.0
| > 0.050−0.139 | 40 | 3.9 | 1.3
| (trend p-value) | | (0.004) | (0.002)
| ^a^Estimated from Figure 1 (Garrett et al., 1999)
Children and adults (stratified)
Palczynski et al. (1999) (Poland); Design: Prevalence study, n = 278 adults ages 16−65 years; n = 186 children ages 5−16 years from 120 households with children (random selection from 10-year-old apartment houses). Participation rate not reported.; Exposure: 24-hour household sample (area not specified) Mean (±SD) (minimum, maximum) 0.026 (±0.011) (0.002, 0.067) mg/m^3^; 2% >0.050.; Outcome: Allergy based on skin prick tests (SPT) to allergens (dust, dust mites, feathers, grasses); Evaluation ^a^; Children:; Medium confidence; Not informative above 0.050 mg/m^3^ because of sample size (≤5).; Adults:; Low confidence; Uncertainty about time window of exposure measurement for skin prick test results (greater uncertainty in adults than in children). Not informative above 0.050 mg/m^3^ because of sample size (≤5). | | Positive Skin | | IgE
| | [underlined: (n)] | [underlined: Prick Test (%)] | [underlined: (>100 kU/L) (%)]
| Children
| <0.025 mg/m^3^ | (101) | 34.7 | 37.6
| 0.025−0.050 | (82) | 28.0 | 32.9
| 0.051−0.067 | (4) | 25.0 | 25.0
| Adults
| <0.025 mg/m^3^ | (142) | 29.6 | 26.1
| 0.025−0.050 | (131) | 28.2 | 25.6
| 0.051−0.067 | (5) | 60.3 | 40.0
| Additional analyses demonstrated effect modification by environmental tobacco smoke, see Table 3-20 in this report.

Results classified as low confidence are shaded gray.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Table 3-13 Allergy symptoms or skin prick tests in relation to formaldehyde exposure in workers

Study and design | | Results
Allergy symptoms
Fransman et al. (2003) (New Zealand); Design: Prevalence study. Plywood mill workers, n = 112. Participation rate 66%. Mean age 34.5 years, 71% men, mean duration 4.7 years.; Exposure: Personal samples (15-minute samples) in jobs held by 49 workers: (n), geometric mean (±geometric standard deviation) (mg/m^3^). | | Allergy symptoms prevalence; Low (<0.080 mg/m^3^, n = 38) 31.6%; High (>0.080 mg/m^3^; n = 11) 45.5%; OR (95% CI) (>0.080 vs. <0080 mg/m^3^): 2.4 (0.5, 11.8); Adjusted for age, sex, ethnicity, smoking. Internal comparison by exposure category limited to the 49 workers with same job titles as those with the 22 air sample measurements. Dust not related to high formaldehyde exposure. Not clear if these specific symptoms were or were not related to other exposures (e.g., endotoxin).
all | (22) 0.080 (3.0)
dryers | (14) 0.070 (3.2) (one outlier)
pressing | (5) 0.160 (2.7)
other areas 0.030−0.040 mg/m^3^ (at or near detection limit)
Total inhalable dust (full-shift personal samples): geometric mean 0.7 mg/m^3^.; Outcome: Self-report, allergy symptoms based on sensitivity to house dust, food, animals, or grasses/plants.; Evaluation^a^:; Low confidence; Uncertain impact of outcome classification (inclusion of food allergies) and uncertainty regarding details of analysis. Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. “Low” exposure group exposed to levels of formaldehyde up to 0.080 mg/m^3^.
Skin prick tests
Herbert et al. (1994) (Canada); Design: Prevalence study. Oriented strand board manufacturing (n = 99). Comparison group (n = 165) oil field workers, not exposed to gas or vapors. Participation rate 98% in workers, 82% in comparison group. Mean age ^~^35 years in both groups.; Exposure: 21 hours continuous area sampling, 2 consecutive days; Saw line, debarking: 0.090−0.160 mg/m^3^; Postheat, press conveyor, packaging, storage: 0.200−0.290 mg/m^3^; Preheat conveyor: 0. 330 mg/m^3^; Total dust: mean 0.27 mg/m^3^, median aerodynamic equivalent diameter = 2.5 μm.; Outcome: Atopy based on skin prick test to six allergens (wheat, rye, Alternaria, cat, house dust, birch; four of these are common allergens in this area).; Evaluation^a^:; Low confidence; Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. Uncertainty about exposures in referent group. Uncertainty about time window of exposure measurement with respect to skin prick test results in adults | | Atopy prevalence not reported
| | OR (95% CI) | 0.75 (0.40, 1.35)
| | Dust exposure considered low; not included in analysis.

Results classified as low confidence are shaded gray.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Asthma

Asthma affects approximately 5−10% of the U.S. population, and results in a significant individual and societal burden in terms of morbidity, health care costs, and indirect costs [e.g., due to absences from work (Shenolikar et al., 2011; Bahadori et al., 2009)]. The potential for formaldehyde to induce or exacerbate asthma symptoms has been described in occupational settings in reports spanning several decades (see for example, (Popa et al., 1969; Nordman et al., 1985)). Characterization of this risk on a population level requires more extensive evaluation. Epidemiological studies have investigated potential associations between formaldehyde and asthma in children and adults using formaldehyde measurements conducted in occupational, residential, and school-based settings. The outcomes studied include the incidence of asthma (i.e., the number of people newly diagnosed with asthma in a period of time),^19^ prevalence of current asthma (typically ascertained through a set of questions pertaining to symptoms or medication use over a period of time, e.g., past 12 months), and asthma control (typically ascertained through a larger set of symptoms, medication, and medical care use over a shorter period of time, e.g., 2−4 weeks). Asthma control pertains to the extent to which symptoms can be reduced or eliminated with medication. The prevalence of current asthma includes newly diagnosed patients, as well as previously diagnosed patients who are experiencing the expression (and thus the costs and burden) of this condition. EPA considered “ever had asthma” to be of limited use in this review, as the formaldehyde measures available do not reflect cumulative exposures that could be related to cumulative risk, and thus EPA did not include results using the definition, “ever had asthma.” However, there were a small number of studies where asthma was not defined clearly but study details appeared to indicate that the definition was not “ever had asthma”; these were included but the limitation was noted. Altered lung function in people with asthma, examined in acute controlled exposure studies, is also discussed in this section, although these acute, high exposure scenarios are of less direct relevance to the question of risks of chronic exposures.

###### Asthma prevalence studies

The collection of studies evaluated associations between formaldehyde exposure and prevalence of current asthma, as determined by symptoms or medication use in the past 12 months. Based on advice from the expert panel consulted by the EPA, this type of questionnaire-based outcome classification used in a cross-sectional design was considered to be an appropriate choice for studies of exposures that could affect the occurrence of asthma episodes. The five medium or high confidence studies in homes or schools with relatively low exposures (<0.05 mg/m^3^, most from approximately 0.02 to 0.04 mg/m^3^) reported relative risks around 1.0 (ranging from 0.72 to 1.14; see Tables 3-14 and 3-15, Figure 3-9). This set of studies included a variety of designs and populations; the school-based studies are large (from 1,014 to 6,683 total participants). The case definition of wheezing during the past year used by Venn et al. (2003) is interpreted to be relevant to a definition of current asthma as used in this assessment since 88% of the cases also reported using a reliever inhaler in the past year.

Seven medium confidence general population studies in children or adults where a proportion of the study sample had exposures of 0.05−0.1 mg/m^3^ (e.g., the 75th percentile was > 0.05 mg/m^3^) were available (see Tables 3-14 and 3-15; Figure 3-9). A hospital-based case-control study of children (mean age 10 years) examined prevalent asthma using the ISAAC questionnaire followed by spirometry results (an FEV_1_ increase of 15% in response to β-agonist inhalation) (Liu et al., 2018). The authors reported an association with formaldehyde levels based on a regression analysis using quartiles of formaldehyde concentration (OR = 2.736, 95% CI: 1.098, 5.516). Exposure levels in the highest quartile ranged from 0.05 to 0.14 mg/m^3^. In a school-based study in Romania, an OR of 2.7 (95% CI: 1.04, 6.97) was seen for asthma symptoms occurring in the past week, a less sensitive and specific outcome compared to “current asthma,” comparing children exposed to formaldehyde at levels of 0.035 to 0.066 mg/m^3^ to the referent group of < 0.035 mg/m^3^ (Neamtiu et al., 2019). Results from a school-based study in Portugal reported an OR of 1.19 (95% CI: 0.60, 2.39) for formaldehyde levels above versus below the median (0.0225 mg/m^3^); the 75^th^ percentile in that study was 0.0646 mg/m^3^ (Branco et al., 2020). Two other studies with relatively high exposures included both children and adults (Zhai et al., 2013; Krzyzanowski et al., 1990), and each provides evidence of a greater susceptibility in children. Both studies compared effects in groups exposed to levels approximately 0.08 mg/m^3^ or above to lower exposed groups; a limitation of the Krzyzanowski et al. (1990) analysis is the relatively small number in the highest exposure group (n = 21), possibly contributing to the imprecision of the effect estimate for that group. Two other medium confidence studies with exposures above 0.05 mg/m^3^ were conducted only in adults (Matsunaga et al., 2008; Billionnet et al., 2011). Billionnet et al. (2011) compared the asthma outcome for subjects exposed to exposures greater than the 75^th^ percentile of 0.028 mg/m^3^ to those exposed to less than the 75^th^ percentile. While most of the study population was exposed to lower concentrations, a portion were exposed to concentrations as high as 0.09 mg/m^3^, which likely influenced the observed RR of 1.4. In the study by Matsunaga et al. (2008) the point estimates were below 1.0 for exposure groups < 0.050 mg/m^3^ but was 2.65 in the highest exposure group (0.058 to 0.161 mg/m^3^); however, the confidence intervals around each of the estimates indicated some imprecision in these estimates (see Figure 3-9).

Epidemiological studies in occupational settings examining the incidence of asthma in a cohort of individuals after they initially enter a workplace have not been conducted. The available studies generally did not attempt to examine the timing of symptoms in relation to when the subjects are present in the workplace (i.e., over the course of a workday or comparison between workdays and weekend days) and so would not have the level of detail that would be included in a clinical workup of occupational asthma; rather, these studies can be thought of as studies of the prevalence of current asthma among workers exposed to formaldehyde. The occupational exposure literature included three medium confidence studies of plywood and other layered wood manufacturing workers in Canada (Herbert et al., 1994), New Zealand (Fransman et al., 2003), and Indonesia (Malaka and Kodama, 1990); each of these studies included between 93 and 112 exposed workers (see Table 3-16). Exposure levels varied by work area, but generally ranged from 0.10 to >0.50 mg/m^3^. A greater than three-fold increased risk of asthma was seen in each of these studies. One of the wood worker studies addressed potential confounding by dust exposure by the inclusion of this variable in the analysis (Malaka and Kodama, 1990), and another study specifically noted that the measured dust levels were not related to high formaldehyde exposure and that the asthma symptoms were not strongly related to other exposures including endotoxin measures (Fransman et al., 2003); these factors provide support for the idea that the associations seen with formaldehyde are not due to confounding by other work-site exposures The results from these studies may represent underestimates of risk; two factors contribute to this concern. All of the studies were prevalence surveys of workers who have remained in a workplace for some time (e.g., 2 or more years), which could be biased by the loss of affected individuals from the workforce (e.g., because of the “healthy worker effect” inherent in this type of study design). In addition, in two of the studies, the comparison group included workers who may have also been exposed to formaldehyde or other respiratory irritants (Herbert et al., 1994; Fransman et al., 2003). Inclusion of this type of exposure in the comparison group reduces the possibility that the observed associations were influenced by differential reporting of asthma among the exposed but raises the possibility that the relative risk estimated against this comparison group underestimates the risk that would be represented by a comparison with a population that does not have these other exposures. Another limitation to note is that the sensitivity and specificity of the symptom-based questionnaire measures may be lower in occupational settings than in general population studies; EPA did not find validation data specific to these types of wood manufacturing settings. However, given the strength of the relative risks, the consistency of the associations seen in the three different workplaces and populations, and the likelihood that the observed associations were underestimates of the true associations, these studies collectively support a strong association between formaldehyde concentrations above approximately 0.100 mg/m^3^ in occupational settings and increased prevalence of current asthma (see Figure 3-9C).

Figure 3-9 Relative risk estimates for prevalence of asthma in children and adults in relation to formaldehyde by exposure level in general population and occupational studies

Study details are described in Tables 3-14 (Panel A), 3-15 (Panel B), and 3-16 (Panel C). Data in children = unfilled symbols; data in adults = filled symbols. Panels represent lower level exposure (circles) and higher level exposure (squares) in general population settings (Panels A and B, respectively); as well as exposure in occupational settings (diamonds, Panel C). High and medium confidence studies are included in the figures. Levels for most of the participants in the study groups in Panel A, low exposure, were < 0.05 mg/m3. Exposure levels in Billionnet et al. (2011) ranged to a maximum of 0.09 mg/m^3^, which resulted in classifying the study as high exposure. Effect estimates are RR or OR. Regarding “mg/m^3^”: for studies which used categorical analysis, mg/m^3^ is midpoint, calculated for the group being compared to the referent group; the mean + 1 SD is used for the continuous analysis conducted by Kim et al. 2011; the 75^th^ percentile was used for the 4-quartile analysis in Liu et al (2018).

Table 3-14 Prevalence of asthma in children in relation to residential or school formaldehyde exposure in studies

Study and design^a^ | Results
High Confidence Studies
Annesi-Maesano et al. (2012) (France); Design: Prevalence study; n = 6,683, ages 9−10 years, participation rate 69%. Sampling from 108 schools, all classes of specified grade level per school.; Exposure: 5-day samples in classrooms.; Median (75th percentile) 0.027 (0.034) mg/m^3^; maximum 0.055 mg/m^3^ (estimated from Figure 1 in paper).; Outcome: Asthma based on ISAAC questionnaire; wheezing or whistling in chest at nighttime; taken asthma treatment in past year.; Evaluation^a^:; High confidence | Prevalence 6.9%, OR (95% CI)
| ≤0.0191 mg/m^3^ | 1.0 | (referent)
| >0.0191−0.0284 | 1.10 | (0.85, 1.39)
| >0.0284−^~^0.055 | 0.90 | (0.78, 1.07)
| (Confidence intervals estimated from Figure 4 in paper.); Adjusted for age, gender, passive smoking, and paternal or maternal history of asthma or allergic disease.; Additional analyses examined effect modification by atopy status, see Figure 3-11 in this report.
Kim et al. (2011) (Korea); Design: Prevalence study; n = 1,028, mean age 10 years, participation rate 96%. Sampling from 12 schools, 2−3 classes per school.; Exposure: 7-day samples in classrooms (n = 34) and one outdoor area per school (n = 12) (all samples collected in same season).; Mean (±SD), (minimum, maximum) 0.028 (±0.0083) (0.016, 0.047) mg/m^3^.; Outcome: Asthma based on current use of asthma medication or asthma attack in past 12 months.; Evaluation^a^:; High confidence | Prevalence of asthma: 6.9%; OR (95% CI), per 0.010 mg/m^3^:; Asthma, current 1.04 (0.78, 1.40).; Adjusted for age, sex, self-reported pet or pollen allergy, environmental tobacco smoke at home, other home environment (indoor dampness, remodeling, changing floor, age of home).
Medium Confidence Studies
Branco et al. (2020) (Portugal); Design: Prevalence study: School children, n=648 preschoolers (3-5 years) and n=882 primary school children (6-10 years) randomly recruited from urban and rural nursery (n=17) and primary schools (n=8), participation rate 39%.; Exposure: Daily exposure based on time-averaged air concentration and reported time in specific school locations. Continuous monitoring in each room (24 h to 9 days). Mean formaldehyde concentration (SD): 0.035 (0.043) mg/m^3^; median, 75^th^ percentile: 0.0225, 0.0646 mg/m^3^ [data provided in email from author to Dr. Glinda Cooper (Branco et al., 2020)].; Outcome: Asthma diagnosis by study physicians based on either reported symptoms using ISAAC questionnaire or a report of ever having 1 or more symptoms plus spirometry before and after bronchodilator (ERS/ATS and Global Initiative for Asthma guidelines).; Evaluation^a^:; Dichotomized analysis:; Medium confidence; Low participation rate, but potential for differential participation (by formaldehyde exposure and disease status) uncertain.; Continuous variable analysis:; Low confidence; Uncertainty regarding interpretation of linear regression given the bimodal distribution of formaldehyde. Uncertainty regarding interpretation of analysis as a continuous variable because of bimodal distribution. | Asthma prevalence: 5.5%; [Medium confidence]; OR (95% CI) above compared to below the median: 1.19 (0.60, 2.39)
| [Low confidence]; OR (95% CI) per IQR increase in exposure:; 0.666 (0.37, 1.21).
| Logistic regression models adjusted for site (urban, rural), study phase, sex, age group, BMI and parental history of asthma. Also controlled for surrogates of home indoor exposure including mother’s education, living with smoker. Other covariates for contact with farm animals during 1st year of life, pets at home in previous year &/or 1st year of life.
Neamtiu et al. (2019) (Romania); Design: Prevalence study; n = 280 children, 89.7% participation rate; Sampling from five primary schools in one county, 3 classrooms per school.; Exposure: 5-day samples in each classroom.; Median (75th percentile) 0.035 (0.045) mg/m^3^, maximum = 0.066 mg/m^3^.; Outcome: Asthma-like symptoms based on ISAAC questionnaire, asthma-like symptoms defined as difficult breathing, dry cough and wheezing in the past week (any symptom).; Evaluation ^a^; Medium confidence; Outcome definition (asthma-like symptoms) is limited to past week. | Asthma-like symptoms (prevalence not reported); OR (95% CI), above compared to below median (0.035 mg/m^3^):; 2.7 (1.04, 6.97); Logistic regression model adjusted for age, gender, NO_2_, CO, CO_2_, temperature, relative humidity, ventilation rate, and tobacco smoke exposure for the past week.
Liu et al. (2018) (China); Hospital based case-control study. n = 180 cases, 180 controls, mean age 10 years, sex, and age comparable. Participation rate not reported.; Exposure: Two-month samples in living room and bedroom. NO_2_ and PM also measured.; Household: median (range), 75^th^ percentile; Cases 0.0384 (0.012–0.142), 0.057 mg/m^3^; Control 0.0251 (0.012–0.094), 0.046 mg/m^3^; Outcome: Asthma diagnosis via ISAAC questionnaire (2 or more incidents of cough, wheezing, and dyspnea for 3 or more consecutive days). Plus, FEV_1_ increased by >15% after β-agonist inhalation and persistent asthma was stable for 3 or more months prior to study.; Evaluation^a^:; Medium confidence; Uncertainty regarding interpretation of formaldehyde as a single variable representing 4 quartiles. | Current asthma; OR (95% CI), formaldehyde by quartile; 2.736 (1.098, 5.516); Regression models adjusted for history of allergy, breastfeeding, ETS and PM_2.5_; Association of lower magnitude (0R = 2.029) also was reported for PM2.5; Note: the units for the odds ratio were not provided, but authors stated that quartiles of concentration were included in the model.
Zhai et al. (2013) (China); Design: Prevalence study; 186 homes from a household survey, with random selection of participants within households; 82 children.; Exposure: Samples in three rooms per house (bedroom, living room, kitchen); sampling time not specified.; 64% of the 186 houses, and 24% of the 82 houses with children were >0.08 mg/m^3^ (“polluted”). Mean formaldehyde levels in the 3 locations 0.09-0.13 mg/m^3^ in the ““polluted” homes and 0.04-0.047 in the “unpolluted” homes; Outcome: (American Thoracic Society questionnaire (physician diagnosed) Ferris (1978).; Evaluation^a^:; Medium confidence; Uncertainty regarding exposure measurement period and validation of case ascertainment in this population. Although potential confounders were not considered in asthma-only analysis, given the magnitude of the results, the formaldehyde association is unlikely to be explained only by confounders. | Prevalence by exposure category:
| | n | (%)
| <0.08 mg/m^3^ | 62 | 3.22
| 0.08−0.15 mg/m^3^ | 20 | 40.0
| RR 12.4 (2.9, 53.7) [calculated by EPA]
Venn et al. (2003) (United Kingdom); Design: Nested case-control study; n = 193 persistent wheeze cases, 214 controls, ages 9−11 years. Participation rate: 54% response to 1998 follow-up of 1995-1996 study; of identified cases and controls, participation was 79% among cases, 59% among controls.; Exposure: 3-day samples in bedroom; median ^~^0.022 mg/m^3^; 75^th^ percentile 0.032 mg/m^3^; median in top quartile 0.041 mg/m^3^.; Outcome: Parent report, wheeze in past year (reported for both of two periods, 1995−1996 and 1998), validated by medical records for 115 cases and 164 controls.; Evaluation^a^:; Medium confidence; Uncertainty regarding impact of loss of subjects between 1995 and 1998. | (n cases), OR (95% CI):
| <0.016 mg/m^3^ | (49) 1.0 | (referent)
| 0.0161−0.022 | (46) 1.14 | (0.65, 2.00)
| 0.0221−0.032 | (51) 1.08 | (0.62, 1.86)
| 0.0321−0.123 | (44) 1.04 | (0.59, 1.82)
| (trend p = 0.93)
| Adjusted for age, sex, socioeconomic status. Venn et al. (2003) did not find that evidence of an adverse effect of NO_2_ or VOCs other than formaldehyde on children’s respiratory health.; Similar results in group with validation of case status from prescription asthma medication records.; (Median in top quartile provided in email from Dr. Venn, March 29, 2012.)
Palczynski et al. (1999) (Poland); Design: Prevalence study; n = 187, ages 5−15 years from 120 households with children (random selection, 10-year old apartments). Participation rate not reported.; Exposure: 24-hour household sample (area not specified).; Mean (±SD) (minimum, maximum) 0.026 (±0.011) (0.002, 0.067) mg/m^3^; 2% >0.050 mg/m^3^; Outcome: Bronchial asthma diagnosed using American Thoracic Society criteria.; Evaluation^a^:; Medium confidence; Uncertainty regarding asthma definition. Not informative above 0.050 mg/m^3^ because of sample size (≤5).; [Data from this study on the sample of adults presented in table above] | Children results: Asthma prevalence 4.8%
| Exposure category | (n) prevalence
| All children
| <0.025 mg/m | (101) 5.0%
| 0.025−0.050 | (82) 4.9%
| 0.0501−0.067 | (4) 0.0%
Krzyzanowski et al. (1990) (United States, Arizona); Design: Prevalence study. n = 298 ages 5−15 years, mean 9.3, from 202 households (stratified sample from municipal employees). Participation rate not reported. 67% white.; Exposure: Two 1-week samples (opposite seasons) in kitchen, living area, and bedroom (converted from ppb); Household: mean 0.032 mg/m^3^; <0.049 mg/m^3^ 83.7%; 0.049−0.074 10.0%; >0.074−0.172 6.3%; Only a few values above 0.111 mg/m^3^; Outcome: American Thoracic Society questionnaire (physician diagnosed) Ferris (1978).; Evaluation^a^:; Medium confidence; For children, relatively small n in higher exposure categories; for adults, incomplete reporting; Related references: Quackenboss et al. (1989a); Quackenboss et al. (1989b).; [Data from this study on the sample of adults presented in table above] | Prevalence:; asthma, current (physician diagnosed) 15.8%; (n), asthma prevalence by exposure category,
| <0.049 mg/m^3^ | (248) 11.7%
| 0.049−0.074 | (24) 4.2%
| >0.074−0.172 | (21) 23.8%
| (trend p < 0.03)
| Log-linear models, stratified by environmental tobacco smoke, adjusted for socioeconomic status, ethnicity.; Highest vs. lowest group: RR (95% CI) 2.0 (0.88, 4.8) (EPA calculation, unadjusted); Additional analyses demonstrated effect modification by environmental tobacco smoke, see Table 121 in this report.
Low Confidence Studies
Yon et al. (2019) (Seongnam City, Korea); Design: Prevalence study, n = 427 school children recruited from 22 randomly selected classrooms at 11 elementary schools; 68.9% participation rate, ages; 10–12 years.; Exposure: Formaldehyde sampling in each classroom using monitors with pumps during the 1st and 2nd half of the school year.; Mean 0.027 ± 0.077 mg/m^3^; as high as 0.06 mg/m^3^ in some classrooms.; Duration and sampling methods were not described.; Outcome: current asthma definition: presence of characteristic symptoms and /or signs during the previous 12 months using ISAAC questionnaire, Self report.; Evaluation^a^:; Low confidence; Uncertainty regarding validation of ISAAC questionnaire in this population; uncertainty regarding exposure measurement period and other protocol details; few (n=10) children with asthma contributed to analyses. | Current asthma prevalence n = 10; OR (95% CI) per 1 µg/m^3^; 1.023 (0.96, 1.089) adjusted for age, sex, environmental tobacco smoke exposure, keeping a pet at home, and physician-diagnosed asthma and allergic dermatitis in parents.
Huang et al. (2017); (Shanghai, China); Design: Case-control study, n = 409 children, aged 5–10 years, who were participants in a previous crosssectional study (2011–2012) selected from 88 kindergartens located in 6 Shanghai districts. Eligible children lived in homes not renovated in prior two years and agreed to home inspection during March 2013-December 2014.; Exposure: Formaldehyde sampling in child’s bedroom, 24 hours, in breathing zone (detection range: 0.012-0.08 mg/m^3^). Mean (± SD) concentration (mg/m^3^), 24-hr 0.0215 (± 0.0130); 75th percentile 0.0275 mg/m^3^; Range 0.006–0.060 mg/m^3^, 3 homes above.; Outcome: Wheezing in past 12 months using selected questions from translated ISAAC questionnaire.; Evaluation^a^:; Low confidence; Participation rate unclear, and potentially differential with respect to exposure and disease status; uncertainty regarding validation of truncated version of ISAAC questionnaire in this population | Current wheezing 27.8%; OR (95% CI) per IQR (15.2 µg/m^3^); 0.93 (0.59, 1.47); Logistic regression adjusted for age, sex, family history of atopy, family annual income, household (ETS), early and current household dampness-related exposures, early antibiotics exposure, early home decoration, and the inspection season.
Madureira et al. (2016) (Porto, Portugal); Design: Case-control study, October 2012–April 2013, random recruitment of 38 residences among asthmatic children and 30 residences among nonasthmatic children previously identified in a cross-sectional study. Mean age 8.5 years. Excluded respondents with a recent renovation or who had moved since responding.; Exposure: Continuous passive sampling in bedroom over 7 days. Formaldehyde concentrations all above the detection limit; see distribution in results column.; Outcome: For asthma cases, parents responded yes to both of 2 questions in ISAAC questionnaire: 1) Has your child ever had asthma diagnosed by a doctor? and 2) In the past 12 months, has your child had wheezing or whistling in the chest? Parents of controls responded no to both questions.; Evaluation^a^:; Low confidence; Potential for selection bias, with greater environmental controls among asthmatic families. Differences in temperature and relative humidity not addressed in analysis. | Formaldehyde concentration in bedroom, mg/m^3^
| | Cases | Controls
| N | 38 | 30
| Mean (SD) | 0.015 (0.010) | 0.017 (0.095)
| Median | 0.011 | 0.015
| IQR | 0.007-0.018 | 0.009-0.022
| Min; Max | 0.004; 0.051 | 0.005; 0.043
| p value = 0.199
Hsu et al. (2012) (Taiwan); Design: Case-control study; n = 9 cases, 42 controls, recruited through kindergartens and day care centers, ages 3−9 years at enrollment (mean age 7.0 years). Participation rate (clinic exam and home measures) approximately 5% of potential cases and controls).; Exposure: 2-hour household sample (probably bedroom; converted from ppb); Median (25th, 75th percentile): Controls 0.017 (0.005, 0.030) mg/m^3^.; Outcome: Initial screening through parent report of history (ages 2−6 years) with confirmation by clinical examination.; Evaluation^a^:; Low confidence; Low and differential (at various steps) participation rate. Short exposure sampling period and no information on protocol. In addition, small sample size (n = 9) for asthma. | Formaldehyde concentrations lower in cases than in controls:; (n) Median (25th, 75th percentile) mg/m^3^
| Controls | (42) 0.017 (0.005, 0.030)
| Asthma cases | (9) 0.005 (0.004, 0.012)
| (p = 0.03); Nonparametric (Mann-Whitney) comparison of formaldehyde by group.
Hwang et al. (2011) (Korea); Design: Case-control study drawn from 1,005 elementary students (one school, all grades; 84% participation rate). 33 cases (out of 129) and 40 controls (out of unspecified number) agreed to participate in environmental measurement study. Controls selected from respondents with no asthma symptoms or diagnosis, age- and sex-matched to cases.; Exposure: 3-day household sample (2 rooms) and personal sample; Geometric mean (±geometric SD) mg/m^3^ in controls: 0.036 (±0.002) household; 0.029 (±0.002) personal; Outcome: Parent report of asthma based on ISAAC questionnaire.; Evaluation^a^:; Low confidence; Asthma definition includes current asthma and ever asthma. Uncertainty regarding selection processes (high prevalence of family history of asthma in cases [86%] and controls [96%]); uncertainty about analysis and distribution of formaldehyde levels | Formaldehyde level, geometric mean (SD) mg/m^3^, by group:
| | Household sample | Personal sample
| Cases | 0.031 (0.002) | 0.027 (0.002)
| Controls | 0.036 (0.002) | 0.029 (0.002)
| OR (95% CI), per unit increase in formaldehyde: 1.0 (1.0, 1.1); Comparison of distributions of exposure (ttests); logistic regression adjusted for gender, age, income, education level of parents, passive smoking.
Hulin et al. (2010) (France); Design: Case-control study; (n = 32 urban cases, 31 urban controls; n = 24 rural cases, 24 rural controls), mean age 12.5 years. Drawn from previous schoolbased surveys. Participation rates 22 and 13% in urban cases and controls, 52 and 75% in rural cases and controls, respectively.; Exposure: 7-day sample in living room; median (minimum, maximum); Total (n = 112) 0.019 (0.004, 0.075) mg/m^3^; Outcome: Parent report of child’s history of asthma, use of asthma medications, or wheezing in past 12 months.; Evaluation^a^:; Low confidence; Small sample size and uncertain interpretation of the stratified analyses (and unspecified n in analysis of current asthma). | OR (95% CI) for above vs. below median); Total sample: 1.7 (0.7, 4.4); urban OR = 0.24 (0.04, 1.5); rural OR = 9.0 (1.0, 98); (interaction p ≤ 0.05); (Confidence intervals estimated from figure in the paper.); Adjusted for age, sex, family history of allergy, passive smoke exposure during childhood, and allergic rhinitis.; Levels of other pollutants that are risk factors for asthma were higher in urban areas.
Choi et al. (2009) (Korea); Design: Case-control study. n = 36 allergic asthma cases, 28 controls, recruited through university outpatient clinic; recruitment procedures not described. Mean age cases 15.4 years (SD = 3.4; controls 16.2 years (SD = 4.1). Housing age and type: cases 58% <3 years old and 72% apartments; controls 29% <3 years old and 50% apartments. Location: 44 and 21% near road for cases and controls, respectively.; Exposure: Household sample (sampling period and area not reported, but closed windows and use of duplicates).; Geometric mean, 25th, and 75th percentiles in controls: 0.043 (0.024, 0.115) mg/m^3^; Outcome: “Allergic asthma” based on medical history, skin prick test, and IgE (criteria not provided).; Evaluation^a^:; Low confidence; Selection and recruitment process not reported; sampling period not reported and specific criteria for case definition not reported; potential confounders (age and type of housing and location differed between cases and controls, as measure of socioeconomic status) not addressed. Limited analysis. | Formaldehyde levels (mg/m^3^):
| | Geometric mean | 75th percentile
| Cases | 0.054 | 0.108
| Controls | 0.043 | 0.115
| p-value not reported (>0.05)
Mi et al. (2006) (Shanghai, China); Design: Prevalence study; n = 1,414, ages 12−17 (mean 13) years, percentage with environmental tobacco smoke not reported, participation rate 99%. Sampling from 10 schools, 3 7th-grade classes per school.; Exposure: 4-hour samples in 30 classrooms. Mean (±SD), (minimum, maximum) 0.009 (±0.0089) (0.003, 0.020) mg/m^3^. No information on LOD or percentage <LOD.; Weak correlation (Spearman r ranged from−0.15 to 0.08) with other exposures (NO_2_ and ozone, indoor and outdoor measurements). Moderate correlation (Spearman r ^~^0.40) with room temperature and relative humidity.; Outcome: Current asthma (medication use or asthma attack in past 12 months), symptoms in past 12 months (wheeze or whistling in the chest, daytime breathlessness attack at rest or after exercise, nighttime breathlessness attack).; Evaluation^a^:; Low confidence; Short exposure measurement period and uncertainty about exposure distribution and analysis (e.g., percentage <LOD and treatment in analysis as continuous variable). | Prevalence of:
| Asthma, current | 3.1%
| Wheeze, whistling | 3.1%
| Daytime attack | 23.0%
| Nighttime attack | 2.6%
| OR (95% CI), per 0.010 mg/m^3^:; Asthma, current 1.30 (0.72, 2.32); Symptoms in past 12 months; Wheeze, whistling 1.01 (0.56, 1.81); Daytime attack 1.09 (0.86, 1.38); Nighttime attack 1.26 (0.63, 2.53); Adjusted for age, gender, smoking, observed water leakage and indoor molds.
Tavernier et al. (2006) (United Kingdom); Design: Case-control study. n = 105 cases, 95 controls (from two primary care practices, age- and sex-matched), ages 4−16 years, lower socioeconomic status. Participation rate 50%.; Exposure: 5-day sample in living room and bedroom.; Outcome: Asthma based on validated screening questionnaire (84% positive predictive value; but included questions on respiratory infection).; Low confidence; Uncertainty regarding selection process and loss of almost half of the cases. Outcome classification includes questions that are not specific to asthma. Uncertainty as to exposure range, particularly upper tertile (no response from email to corresponding author).; Related Reference: Gee et al. (2005) | OR (95% CI), by exposure tertile (exposure levels not reported; median in Gee et al. (2005) reported as 0.037 and 0.049 mg/m^3^ in living room and bedroom, respectively)
| | Living room | Bedroom
| Lowest | 1.0 (referent) | 1.0 (referent)
| Middle | 0.82 (0.33, 2.05) | 1.26 (0.47, 3.40)
| Highest | 1.22 (0.49, 3.07) | 0.99 (0.39, 2.52)
| Odds ratio, conditional logistic regression, adjusted for measured exposures (e.g., endotoxin, Der p 1, particulate matter) and other risk factors.
Smedje and Norback (2001) (Sweden).; Design: Prospective (incidence) nested case-control study. 1,258 without asthma at baseline, 56 incident cases of asthma in 4-year follow-up (incidence rate 1.1% per year); 78% participation in follow-up, mean age 10.3 years at baseline. School-based sample; 1st, 4th, and 7th grades.; Exposure: Two 4-hour samples in 2−5 classrooms per school; measured in 1993 (n = 98) and 1995; (n = 101).; Mean 0.008 mg/m^3^, geometric mean 0.004 mg/m^3^, (min, max) (<0.005, 0.072) mg/m^3^, 54% of 1993 samples and 24% of 1997 samples below detection limit (0.005 mg/m^3^); median among those above detection limit = 0.010 mg/m^3^. Individual student values based on average of 1993 and 1997 classrooms (<0.005 to 0.042 mg/m^3^).^c^; Outcome: Parent report of physician diagnosis of asthma and six lower respiratory symptom questions; previous validation study (73% sensitivity, 99% specificity).; Analysis: Odds ratio, adjusted for sex, age, history of atopy, smoking.; Evaluation^a^:; Low confidence; Exposure measures in only 2 of the 4 years and 2/3 of students left the school more than a year before follow-up; uncertainty about distribution; relatively high percentage <LOD. Confounding by other exposures not fully addressed but pattern of results differed among the exposures examined.; Related Study: Smedje et al. (1997). | OR (95% CI) per 0.010 mg/m^3^:; total sample: 1.2 (0.8, 1.7); with history of atopy: 0.6 (0.3, 1.3); no history of atopy: 1.7 (1.1, 2.6); (Atopy defined at baseline based on positive response to questions on childhood eczema, allergy to pollen, or allergy to pet dander.); Additional analyses examined effect modification by atopy status, see Figure 3-11 in this report.
Garrett et al. (1999) (Australia); Case-control study. 53 cases (physician diagnosis), 95 controls (no asthma diagnosis) from 80 households (some cases and controls from same household), ages 7−14 (mean 10.2) years.; Exposure: 4-day (1 per season) measures in home (bedroom, living room, kitchen), and outdoors.; Median (maximum) Indoor 0.0158 (0.139) mg/m^3^; Outcome: Parent report, doctor-diagnosed asthma, and respiratory symptom questionnaire.; Evaluation^a^:; Low confidence; Uncertainty about asthma definition (current asthma or ever asthma?). Uncertainty about effect of recruitment process and ability to fully address household correlation of cases and controls; could result in attenuated effect estimate. Incomplete reporting of results (adjusted results reported as “not statistically significant”). | Incomplete reporting of results; (n), proportion with asthma (overall proportion 53/148 = 0.36):
| <0.020 mg/m^3^ | (31) 0.16
| 0.020−0.050 | (76) 0.39
| >0.050−0.139 | (41) 0.44
| (trend = 0.02)
| Adjusted for parental asthma history, sex.; Adjusted results reported as “not statistically significant” (numeric results not reported).

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

a Evaluation of sources of bias or study limitations (see Appendix B.3.4). Direction of anticipated bias is indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact is likely to be away from the null (i.e., spurious or inflated effect estimate).

Table 3-15 Prevalence of asthma in adults in relation to residential formaldehyde exposure

Study and design^a^ | Results
Medium Confidence Studies
Billionnet et al. (2011) (France); Design: Prevalence study, n = 905 adults from 490 dwellings (drawn from nationally representative sample; 13.6% participation rate), median age 44 (15−89) years; 48% men.; Exposure: One-week sample in bedroom; Median, 75th percentile (minimum, maximum) 0.0194, 0.028 (0.0013, 0.0863) mg/m^3^; Outcome: Asthma based on self-report, asthma attack, woken by shortness of breath, or using asthma medication in past 12 months; Evaluation^a^:; Medium confidence; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. | Prevalence of asthma: 8.6%; OR (95% CI), adjusted for multiple risk factors, above vs. below 75th percentile (0.028−0.0863 vs. <0.028 mg/m^3^):; 1.43 (0.8, 2.4); (Confidence intervals estimated from graph); Adjusted for age, gender, smoking status, relative humidity, mold, pets, outdoor sources of pollution within 500-meter radius, highest education level in household, time of data collection.
Matsunaga et al. (2008) (Japan); Design: Prevalence study. Adults, n = 998 women, mean 17th week of pregnancy, median age ^~^30 years.; Recruited through obstetric clinics and public health nurses. Osaka prefecture, Japan. Participation rate 17% of pregnant women in the area.; Exposure: 24-hour personal sample (converted from ppb); Median 0.030, maximum 0.161 mg/m^3^; Cutpoints based on 30th, 60th, and 90th percentiles (<0.022, 0.022−0.033, 0.034−0.57, and ≥0.058 mg/m^3^); Outcome: Self-report, treatment for asthma in past 12 months; Evaluation^a^:; Medium confidence; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. Some uncertainty pertaining to sensitivity and specificity of outcome assessment, but considered adequate | Asthma (2.1% prevalence)
| mg/m^3^ | n | OR | (95% CI)
| <0.022 | 298 | 1.0 | (referent)
| 0.022−0.033 | 299 | 0.80 | (0.23, 2.84)
| 0.034−0.057 | 301 | 0.72 | (0.19, 2.77)
| 0.058−0.161 | 100 | 2.15 | (0.41, 11.3)
| (trend p-value = 0.47)
| 0.058 to 0.161 vs. <0.058 | | 2.65 | (0.63, 11.1)
| Adjusted for age, gestation, parity, family history (asthma, atopic eczema, allergic rhinitis), smoking, passive smoking, mold in kitchen, indoor domestic pets, dust mite antigen level, family income, education, season of data collection.
Palczynski et al. (1999) (Poland); Design: Prevalence study; n = 278, ages 16−65 years from 120 households with children (random selection, 10-year old apartments). Participation rate not reported.; Exposure: 24-hour household sample (area not specified).; Mean (±SD) (minimum, maximum) 0.026 (±0.011) (0.002, 0.067) mg/m^3^; 2% >0.050 mg/m^3^; Outcome: Bronchial asthma diagnosed using American Thoracic Society criteria.; Evaluation^a^:; Medium confidence; Uncertainty regarding asthma definition. Not informative above 0.050 mg/m^3^ because of sample size (≤5). [Data from this study on the sample of children presented in table above] | Asthma prevalence: 5.8%; Exposure category (n) prevalence; All adults; <0.025 mg/m^3^ (142): 6.3%; 0.025−0.050 (131): 4.6%; 0.0501−0.067 (5): 20.0%
Krzyzanowski et al. (1990) (United States, Arizona); Design: Prevalence study. n = 613 ages >15 years, mean 37) from 202 households (stratified sample from municipal employees). Participation rate not reported. 67% white.; Exposure: Two 1-week samples (opposite seasons) in kitchen, living area, and bedroom (converted from ppb) Household: mean 0.032 mg/m^3^; <0.049 mg/m^3^ 83.7%; 0.049−0.074 10.0%; >0.074−0.172 6.3%; Only a few values above 0.111 mg/m^3^; Outcome: American Thoracic Society questionnaire (physician diagnosed) Ferris (1978).; Evaluation^a^:; Medium confidence; For children, relatively small n in higher exposure categories; for adults, incomplete reporting; Related references: Quackenboss et al. (1989a); Quackenboss et al. (1989b).; [Data from this study on the sample of children presented in table above] | Prevalence of asthma: 12.9%; wheeze without a cold: 21.5%; shortness of breath with wheezing: 14.0%; Reported as “not significantly related” but rate of wheeze was “somewhat higher” with higher exposure.
Low Confidence Studies
Zhai et al. (2013) (China); Design: Prevalence study, with random selection of participants within households; 186 homes 186 adults.; Exposure: Samples in three rooms per house (bedroom, living room, kitchen); sampling time not specified.; 64% of the 186 houses, and 24% of the 82 houses with children were >0.08 mg/m^3^ (“polluted”). Mean formaldehyde levels in the 3 locations 0.09-0.13 mg/m^3^ in the ““polluted” homes and 0.04-0.047 in the “unpolluted” homes; Outcome: (American Thoracic Society questionnaire (physician diagnosed) Ferris (1978).; Evaluation^a^:; Low confidence; Uncertainty regarding exposure measurement period and validation of case ascertainment in this population. Although potential confounders were not considered in asthma-only analysis, given the magnitude of the results, the formaldehyde association is unlikely to be explained only by confounders.; For adults, small number (n=2) of positive responses. Data from this study on the sample of children presented in table above] | Prevalence by exposure category; Adults; n (%); <0.08 mg/m^3^ 66 (0.0); 0.08−0.15 mg/m^3^ 120 (1.6); RR not calculated
Norback et al. (1995) (Sweden); Design: Nested case-control within random population sample; n = 47 cases, n = 41 controls, ages 20−44 (mean 32) years. Participation rate 64 and 57%, respectively, among selected cases and controls.; Exposure: 2-hour sample measured in bedroom.; Mean (Min, Max) 0.029 (<0.005, 0.110) mg/m^3^. Strongly correlated with total volatile organic compounds (correlation coefficient not shown).; Mean duration in home = 6 years (minimum 0.5, maximum 31).; Outcome: Cases defined by positive response to: asthma attack in past 2 months, nocturnal breathlessness in past 12 months, or current use of asthma medication.; Controls responded “no” to all three questions.; Evaluation^a^:; Low confidence (↑); Uncertainty about exposure (most values <LOQ). Similar results for volatile organic compounds, and not possible to distinguish effects of formaldehyde and these other compounds; could result in inflated effect estimate. | Mean (minimum, maximum) formaldehyde levels for nocturnal breathlessness:
| With symptom | 0.029 (<0.005, 0.110) mg/m^3^
| Controls | 0.017 (<0.005, 0.060) mg/m^3^
| (p < 0.01)
| OR 12.5 (2.0, 77.9) per 10-fold increase in formaldehyde (log-transformed), similar results for volatile organic compounds.; Odds ratio, adjusted for age, sex, current smoking, wall-to-wall carpets, and house dust mites.
Low Confidence Studies: Combined analysis of adults and children
Yeatts et al. (2012) (United Arab Emirates); Design: Prevalence studyurvey; n = 1,590 (1,007 ages 19−50 years, 583 ages 6−18 years from 628 nationally representative sample of household (75% household participation).; Outcome: Asthma, wheeze symptoms based on several standardized questionnaires.; Analysis: Odds ratio, adjusted for sex, urban/rural area, age group, household tobacco smoke; children and adults combined in analysis.; Exposure: 7-day sample (living room); 71% <limit of quantification (0.0074 mg/m^3^); 95th percentile 0.059 mg/m^3^; 99th percentile 0.114 mg/m^3^ (converted from ppm); Correlation with sulfur dioxide relatively high (r = 0.63); also higher in homes using incense >1 per week; Evaluation^a^:; Low confidence (↑); Difficult to disentangle possible effects of sulfur dioxide from those of formaldehyde (similar effect sizes; moderate–strong correlation; could result in inflated effect estimate. Does not separate analysis of children and adults; only 29% above LOD―analyzed as above vs. below LOD | | | Prevalence % | OR (95% CI)
| Wheezing in past 12 months | | 9.2 | 0.64 (0.71, 2.42)
| Wheezing in past 4 weeks | | 6.1 | 3.5 (0.81, 14.9)
| Difficulty breathing or chest tightness in past 12 months | | 12.0 | 1.43 (0.83, 2.46)
| Difficulty breathing or chest tightness once or more times a month | | 7.0 | 6.5 (1.9, 22.3)
| Similar results seen with sulfur dioxide.
| Odds ratio, adjusted for sex, urban/rural area, age group, household tobacco smoke; children and adults combined in analysis.

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Table 3-16 Prevalence of asthma in relation to occupational formaldehyde exposure

Study and design^a^ | Results
Medium Confidence Studies
Fransman et al. (2003) (New Zealand); Design: Prevalence study. Plywood mill workers, n = 112. Participation rate 66%. Mean age 34.5 years, 71% men, mean duration 4.7 years. Internal comparison by exposure level and external comparison group (n = 415) from general population (random sample) surveys in the study area.; Exposure: Personal samples (15-minute samples) in jobs held by 49 workers: (n), geometric mean (±geometric standard deviation) (mg/m^3^); none exceeded 1.25 mg/m^3^; all (22) 0.080 (3.0); dryers (14) 0.070 (3.2) (one outlier); pressing (5) 0.160 (2.7); other areas 0.030–0.040 mg/m^3^ (at or near detection limit); Total inhalable dust (full-shift personal samples): geometric mean 0.7 mg/m^3^.; Dust levels highest among composers; formaldehyde levels in this group were <detection limit (0.030 mg/m^3^); Outcome: Current use of asthma medications or history in past 12 months of an asthma attack or being woken by shortness of breath; Evaluation^a^:; Medium confidence (↓); Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. “Low” exposure group exposed to levels of formaldehyde up to 0.080 mg/m^3^. Either limitation could result in reduced (attenuated) effect estimate. | Prevalence of asthma in exposed workers, external comparison group 20.5%, 12.5%
| | (n) | OR (95% CI):
| All workers | (112) | 1.5 (0.9, 2.8)
| By duration:
| <2 years | (34) | 0.5 (0.2, 1.7)
| 2–6.5 years | (39) | 1.0 (0.3, 2.7)
| >6.5 years | (39) | 3.1 (1.3, 7.2)
| By category:
| Low (<0.080 mg/m^3^) (38) 1.0 (referent)
| High (>0.080 mg/m^3^) (11) 4.3 (0.7, 27.7)
| Weaker association with terpenes (OR 2.0 for high vs. low exposure); no association with other exposures (e.g., dust, endotoxin) examined in this study.
| Adjusted for age, sex, ethnicity, smoking.
| Internal comparison by exposure category based on job title (limited to workers with same job titles as those with the 22 air sample measurements).
Herbert et al. (1994) (Canada); Design: Prevalence study. Oriented strand board manufacturing (n = 99).; Comparison group (n = 165) oil field workers, not exposed to gas or vapors.; Participation rate 98% in workers, 82% in comparison group. Mean age ^~^35 years.; Exposure: 21 hours continuous area sampling, two consecutive days; Saw line, debarking: 0.090–0.160 mg/m^3^; Postheat, press conveyor, packaging, storage 0.200–0.290 mg/m^3^; Preheat conveyor 0.330 mg/m^3^; Total dust: mean 0.27 mg/m^3^, median aerodynamic equivalent diameter = 2.5 μm; Outcome: International Union Against Tuberculosis and Lung Disease (1986) questionnaire (symptoms past 12 months).; Evaluation^a^:; Medium confidence (↓); Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. Uncertainty about exposures in referent group. Either limitation could result in reduced (attenuated) effect estimate. | Prevalence in exposed workers, comparison group
| Asthma | | 13.3%, 3.0%
| Wheeze attacks | | 25.3%, 9.7%
| Woken by shortness of breath | | 8.1%, 1.2%
| OR (95% CI)
| Asthma | | 5.48 (1.85, 16.2)
| Wheeze attacks | | 3.34 (1.66, 6.73)
| Woken by shortness of breath | | 6.78 (1.40, 32.7)
| Adjusted for age, smoking. Dust exposure considered low, not included in analysis.
Malaka and Kodama (1990) (Indonesia); Design: Prevalence study. Plywood workers, n = 93 exposed (93% participation rate), 93 unexposed from same plant, matched by age, ethnicity, smoking history (all men). Mean age ^~^27 years, mean duration 6 years.; Exposure: Personal and area samples (duration not reported); Mean by area (converted from ppm); Exposed―Plywood: 0.78 mg/m^3^; Particle board: 2.9 mg/m^3^; Block board:; 0.62 mg/m^3^; Other (“unexposed”): ≤0.086 mg/m^3^; Outcome: Ferris (1978) questionnaire. Asthma based on “ever had attack of wheezing that made you feel short of breath?” or ever diagnosed with asthma and experienced currently; occupational asthma not defined.; Evaluation^a^:; Medium confidence; Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. “Unexposed” exposure group exposed to levels of formaldehyde up to 0.086 mg/m^3^. Either limitation could result in reduced (attenuated) effect estimate. Unclear definition of asthma used in the analysis: “Occupational asthma” not defined, and lack of clarity in asthma definition pertaining to current prevalence. | Prevalence in exposed workers, comparison group:
| Occupational asthma | | 14%, 8%
| Asthma | | 30%, 8%
| OR (95% CI):
| Occupational asthma
| 2.84 (not reported) (p = 0.02)
| Asthma
| 6.31 (not reported) (p < 0.01)
| Adjusted for age, smoking, dust
Low Confidence Studies
Neghab et al. (2011) (Iran); Design: Prevalence study, melamine-formaldehyde resin plant, n = 70 exposed, 24 unexposed (office workers from same plant, no present or past exposure to formaldehyde or other respiratory irritant chemicals; all men). Similar demographics, smoking history. Participation rate 100%. Duration ≥2 years.; Exposure: Area samples (40 minutes) in seven workshops and one area sample in office area (converted from ppm); Exposed (mean ±SD) 0.96 (±0.49) mg/m^3^; unexposed nondetectable; Outcome: Ferris (1978) questionnaire, wheezing symptoms (period not specified).; Evaluation^a^:; Low confidence; Selection out of the exposed work force of “affecteds” possible in this type of prevalence study; could result in reduced (attenuated) effect estimate. Potential low specificity and low sensitivity of outcome measure; no covariates. | Prevalence in exposed workers, comparison group:; Wheezing symptoms 48.6%, 8.3%;; OR (95% CI not reported) OR 10.4; (p = 0.001)
Holness and Nethercott (1989) (Canada); Design: Prevalence study, funeral home workers, n = 84 exposed (funeral directors and apprentices); 38 unexposed (from community service organization and students). Participation rate 87% of invited funeral home workers. Average exposure (embalming) duration 10 years.; Exposure: 2 area samples during embalming, 30 to 180 minutes.; Range in exposed 0.10–1.0 mg/m^3^, referent mean 0.025 mg/m^3^; Outcome: Ferris (1978) questionnaire: wheeze (no details of questions).; Evaluation^a^:; Low confidence; Uncertainty regarding asthma definition. Differences in source populations for exposed and referent groups lead to uncertainty in comparability. No consideration of potential confounding. | Prevalence in exposed workers, comparison group:; Wheeze 19%, 11% p = 0.32

Organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

a Evaluation of sources of bias or study limitations (see Appendix B.3.4). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious, or inflated effect estimate).

###### Asthma control studies

The previous discussion focused on the association between formaldehyde and prevalence of current asthma (i.e., symptoms or use of medications in the past 12 months). A different question concerns the association between formaldehyde and asthma control among people with asthma. This population could represent a group with greater susceptibility or vulnerability than the general population. EPA identified two observational studies that examined symptom frequency and medication use in the past 4 weeks and an intervention study that examined symptoms and medical care utilization in 12 months before and after an air quality control measures were taken to reduce residential formaldehyde levels (see Table 3-17). These studies provide additional support for the effects of formaldehyde exposure among children with asthma at levels at or below those seen in the studies of formaldehyde in relation to the prevalence of asthma.

In the United Kingdom, Venn et al. (2003) examined symptoms recorded in daily diaries over the course of 1 month in relation to formaldehyde levels measured in the child’s home (3-day samples from bedrooms). No association was seen with the prevalence of wheezing during the past year in the case-control analysis (as discussed in the previous section), but among the 193 cases, a two- to three-fold increased risk of frequent symptoms (defined as symptoms recorded on ≥10 consecutive days) was seen in the highest quartile of exposure (>0.032 mg/m^3^) compared with exposures <0.016 mg/m^3^, with some evidence of an increased risk at even lower exposures (see Figure 3-10; p-value for trend = 0.05). For nighttime symptoms, which may be most relevant with respect to measurements taken in the bedroom, the relative risk estimate was 3.33 (95% CI 1.23, 9.02; p-value for trend = 0.02). The case definition of wheezing during the past year is interpreted as relevant to the definition of current asthma as used in this assessment, since 88% of the cases also reported using a reliever inhaler in the past year. These results were not impacted by inclusion of measures of room dampness in the models and were stronger when limited to patients with atopy (based on positive skin prick test results). Venn et al. (2003) did not find evidence of an adverse effect of NO_2_ or VOCs other than formaldehyde on children’s respiratory health. In a smaller study of 37 low-income children in Boston, Dannemiller et al. (2013) observed higher formaldehyde levels in homes of children with poor asthma control compared to those with better asthma control (geometric mean 0.066 and 0.042 mg/m^3^, p = 0.078).

###### Intervention studies

A randomized controlled trial measured the impact of an intervention on indoor air contaminants (including formaldehyde) on symptom exacerbation among asthmatic children (Lajoie et al., 2014). A 50% reduction in formaldehyde concentrations in the bedroom was associated with a 14 to 20% decrease in the annual change in some symptoms or medical care (one or more episodes of wheezing, night cough, or one or more emergency room visit; p-values between 0.01 and 0.037) in the intervention group (Lajoie et al., 2014). Smaller reductions (7–11% decreases) were seen for more severe outcomes (severe wheezing, ≥ 4 episodes wheezing, ≥ 1 hospitalization, p-values between 0.17 and 0.25). Pre-intervention, formaldehyde levels in 30% of the intervention home were > 0.050 mg/m^3^; post-intervention all formaldehyde levels were < 0.050 mg/m^3.^ Other coexposures were reduced by the intervention resulting in uncertainty in the independent effect of formaldehyde, although the reductions were smaller in magnitude and separate effects of the other factors were not analyzed.

Figure 3-10 Relative risk of persistent wheeze and of increased frequency of symptoms among children with wheeze in relation to residential formaldehyde exposure

Effect modification by disease status: comparison of formaldehyde associations with prevalence of current asthma (persistent wheeze) and with increased frequency of symptoms only among cases. Data from Venn et al. (2003); study details in Table 3-17.

Table 3-17 Exacerbation of asthma symptoms in relation to residential formaldehyde exposure

Study and design^a^ | Results
Observational Studies
Venn et al. (2003) (United Kingdom); Design: Nested case-control study; Symptom control among persistent wheeze cases (symptoms during past year) (n = 193), ages 9–11 years.; Participation rate 79%.; Exposure: 3-day samples in bedroom during home visit.; Median ^~^0.022 mg/m^3^; 75th percentile 0.032 mg/m^3;^; Median in top quartile 0.039 mg/m^3^; [Maximum and median in top quartile provided in email from Dr. Venn to Glinda Cooper, March 29, 2012; (Venn, 2012)]; Outcome: 1-month daily diaries recording symptoms: daytime and nighttime wheezing, chest tightness, breathlessness, and cough, each measured on 0-to-5 scale. “Frequent” symptoms defined as recorded on ≥10 days.; Evaluation:; High confidence | (n cases, percentage with frequent symptoms), OR (95% CI):
| Frequent nighttime symptoms
| <0.016 mg/m^3^ | (39, 41%) | 1.0 (referent)
| 0.0161–0.022 | (35, 49%) | 1.40 (0.54, 3.62)
| 0.0221–0.032 | (36, 53%) | 1.61 (0.62, 4.19)
| 0.0321–0.083 | (33, 67%) | 3.33 (1.23, 9.01)
| (trend p = 0.02)
| OR per quartile increase:
| full sample | | 1.45 (1.06, 1.98)
| limited to atopic cases | | 2.06 (1.37, 3.09)
| Frequent daytime symptoms
| <0.016 mg/m^3^ | (37, 62%) | 1.0 | (referent)
| 0.020–0.022 | (34, 47%) | 0.47 | (0.17, 1.25)
| 0.022–0.032 | (37, 73%) | 2.00 | (0.71, 5.65)
| 0.032–0.083 | (32, 73%) | 2.08 | (0.71, 6.11)
| (trend p = 0.05)
| OR per quartile increase:
| full sample | | 1.40 (1.00, 1.94)
| limited to atopic cases | | 1.68 (1.10, 2.57)
| Odds ratio, adjusted for age, sex, and Carstairs deprivation index
| Additional adjustment for dampness or other exposures including visible mold, total VOCs, or NO_2_, did not affect formaldehyde results.
| No evidence of an adverse effect of NO_2_ or VOCs other than formaldehyde on children’s respiratory health.
| Similar results in group with validation of case status from prescription asthma medication records.
Dannemiller et al. (2013) (United States); Design: Symptom control among 37 asthma cases, mean age 10.5 years. Participation rate 79% (37 out of 47); Exposure: 30-minute pumped sample in kitchen (converted from ppb); Median 0.044 mg/m^3^; Range 0.006–0.162 mg/m^3^; 31% >0.060 mg/m^3^; Outcome: Five-question survey about symptom control in past 4 weeks at same time as environmental sampling.; Evaluation^a^:; Medium confidence; Recruitment is not from a well-defined population.; Limited exposure measurement period (but quality control details provided, and none were < LOD).; Related reference: Sandel et al. (2014) | Asthma Control Question
| Geometric mean formaldehyde (mg/m^3^)
| Frequency during past 4 weeks | N (%) with most severe rating | Most severe group | All other groups | p-value
| Asthma interfered with activities | 5 (14%) | 0.070 | 0.042 | 0.066
| Shortness of breath | 3 (8%) | 0.079 | 0.043 | 0.086
| Nighttime symptoms | 4 (11%) | 0.065 | 0.043 | 0.184
| Used rescue inhaler or nebulizer medication | 4 (11%) | 0.055 | 0.044 | 0.409
| Asthma control rating | 3 (8%) | 0.074 | 0.043 | 0.128
| Score <12 (very poor control) | 6 (16%) | 0.066 | 0.042 | 0.078
| Similar results adjusted for season.
| Examined season, temperature, and relative humidity in the analysis
Intervention Studies
Lajoie et al. (2014) (Quebec, Canada); Design: Intervention study October 2008–June 2011, n = 43 intervention group, n = 40 control group; Asthmatic children with exacerbation requiring medical care in the past year referred by physicians at tertiary care center, 3–12 years old, (n=83, 71.5% of those meeting inclusion criteria) in homes with low ventilation rates [<0.30 air exchange per hour (ACH)). Randomly assigned to intervention to increase ventilation rates by 0.15 ACH.; Exposure: Passive air sampling for formaldehyde in bedroom, 6–8 days, during winter and summer seasons;; Outcome: Symptom prevalence (rhinitis and asthma) over last 12 months based on ISAAC questionnaire administered to parents pre- and post-intervention. Also include questions on asthma control and a daily symptom diary completed for two weeks per month in November through March for both the pre- and the post-intervention years.; Evaluation:; Medium confidence; Other coexposures that have been associated in literature with asthma symptoms also declined in intervention group (toluene, ethylbenzene, styrene, limonene, alpha-pinene, airborne mold spores), although formaldehyde reduction was greatest. | Asthma symptoms
| Change from year 1 to year 2 in prevalence of asthma symptoms and medical care in the past year associated with a 50% reduction in formaldehyde concentration. Analyses in intervention group, n = 43:
| Outcome ≥ 1 episode | % Change (95% CI) | p value
| Wheezing | −14.8 (−28.6, −0.9) | 0.037
| Night cough | −20.4 (−35.7, −5.0) | 0.010
| ≥ 1 emergency Room visit | −16.0 (−30.5, −1.5) | 0.031
| Analyses used mixed linear models with repeated measures. adjusted for age and eczema.
| Other outcomes analyzed with smaller reductions were disturbed sleep (−15.7%, change, p = 0.130), ≥ 4 episodes wheezing −7.2% change, p = 0.255), effort wheezing (−9.1% change, p = 0.173) and 1 or more hospitalization (−7.9% change, p = 0.218). There was no change or nonsignificant increases in severe wheezing (1.5% change, p = 0.888) and rhinitis (11.0% change, p = 0.105).
| Change in exposure levels:
| Intervention group pre- and post-intervention, Fall/winter measurements: Pre-geometric mean 0.037 (0.032–0.043) mg/m^3^; 30.1% homes ≥ 0.050 mg/m^3^; post- geometric mean 0.024 (0.021–0.028) mg/m^3^; 0% homes ≥ 0.050 mg/m^3^;
| Control group, pre- geometric mean 0.037 (0.031–0.043) mg/m^3^; 25.5% homes ≥ 0.050 mg/m^3^; post- geometric 0.035 (0.030–0.041) mg/m^3^; 22.9% homes ≥ 0.050 mg/m^3^.

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4).

###### Acute exposure―controlled chamber studies―people with asthma

Most of the acute formaldehyde exposure studies among adults with asthma provide little or no evidence of an immediate effect on pulmonary function in response to formaldehyde inhalation (see Table 3-18); however, no controlled exposure studies have been conducted in children with asthma. The exposure duration in these studies ranges from 10 minutes to 3 hours, and so does not represent a chronic exposure scenario. The studies are fairly small (ranging from 7 to 19 participants) and use various measures of pulmonary function (e.g., FEV_1_, FVC) and airway reactivity. Only two of these studies included an assessment of the response to an allergen challenge: dust mite in Casset et al. (2006) and grass pollen in Ezratty et al. (2007). One of these studies demonstrated a reduction in the average dose of mite allergen required for a 20% decrease in FEV_1_ from baseline (PD_20_ FEV_1_) after a 30-minute exposure via mouth breathing only to 0.092 m/m^3^ of formaldehyde compared to ambient air controls (0.032 mg/m^3^ formaldehyde) [54.7 ng versus 73.2 ng, respectively; (Casset et al., 2006)]. Formaldehyde exposure also increased the late-phase response, expressed as the maximum fall in FEV_1_ from baseline observed during the 6-hour follow-up, by 15% in FEV_1_ in the exposed individuals compared to an 11% reduction among controls. However, these effects were not observed in the study by Ezratty et al. (2007). One difference in these studies is that the Casset et al. (2006) protocol used a nose clip, thus resulting in inhalation solely by mouth. In addition, for all of these studies, the severity of asthma among the volunteers in these experiments is not known; thus, the results may not be generalizable to all people with asthma.

Table 3-18 Controlled acute exposure chamber studies of pulmonary function with formaldehyde exposure among people with asthma

Study and design | Exposure measures | Results
Study and design | Exposure measures | Pulmonary function | | | | Bronchial challenge―airway reactivity
Studies with allergen challenge
Ezratty et al. (2007); n = 12, ages 18–44, nonsmoking, positive history of pollen allergy.; Design: Random assignment to order of exposure (2 weeks apart); double blinded. Testing pre-exposure and every hour up to 8 hours postexposure. Grass pollen (5 allergens) challenge (protocol described).; Evaluation^a^:; High confidence | 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Early phase response―PD_15_ FEV_1_ grass allergen: compared with placebo, higher in five subjects and unchanged in seven after exposure.
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Median (range) index of reactivity:
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Placebo | 0.25 (0.10–2.0)
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Exposed | 0.80 (0.15–2.0)
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | (p = 0.06)
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Late-phase response (8 hours postexposure and allergen challenge)
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | PD_15_ FEV_1_
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Placebo | 0.17 (0.03–4.0)
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | Exposed | 0.23
| 60 minutes, 0 and 0.500 mg/m^3^ | No difference in FVC or FEV_1_ before or immediately after (data not shown) | | | | (0.01–3.6) (p = 0.42)
Casset et al. (2006); n = 19, ages 19–35 years, nonsmoking, positive IgE to dust mites.; Design: Random assignment to order of exposure (3 weeks apart); double blinded. Mean formaldehyde exposure at home 0.037 ± 0.004 mg/m^3^ (24hour sample). Testing pre-exposure and every hour up to 6 hours postexposure. House dust mite challenge (Der p 1 11.08 μg/mL, 11.12 μm) (protocol described).; Evaluation^a^:; High confidence; Note: applies to mouth breathing. | 30 minutes, 0.032 (background) and 0.092 mg/m^3^ Nose clip (breathing by mouth) | No difference in at-pretreatment or early-posttreatment assessment; Late-phase response―Mean ± SE reduction FEV_1_:; Placebo 11 ± 1.6; Exposed 15 ± 1.6 (p = 0.046) | | | | Early phase response―PD_20_ FEV_1_ Der p1; Mean ± SE; median (ng):; Placebo 73.2 ± 17.3; 39.7; Exposed 54.7 ± 12.6; 28.1; (p = 0.05)
Studies without allergen challenge
Witek et al. (1986); Witek et al. (1987)^b^; n = 15, ages 18–35 years, nonsmoking; Design: Two protocols (at rest and during exercise). Random assignment to order of exposure; double blinded. Testing during and at 10 and 30 minutes postexposure; PEFR assessed from 1 to 24 hours postexposure.; Evaluation^a^:; High confidence; Note: nonparametric analysis could be preferred but individual data provided | 40 minutes, 0 and 2,000 ppb [0, 2.46 mg/m^3^] | Few differences in FVC, FEV_1,_ R_aw_, or other lung function measures; At 30 min postexposure, resting protocol | | | | PD_20_ FEV_1_ mean ± SD; median Pre-exposure:; 24.0 ± 15.7; 27.4; Postexposure:; 13.6 ± 20.5; 3.1; (p = 0.12)
| 40 minutes, 0 and 2,000 ppb [0, 2.46 mg/m^3^] | | FVC | FEV_1_ | R_aw_ | PD_20_ FEV_1_ mean ± SD; median Pre-exposure:; 24.0 ± 15.7; 27.4; Postexposure:; 13.6 ± 20.5; 3.1; (p = 0.12)
| 40 minutes, 0 and 2,000 ppb [0, 2.46 mg/m^3^] | Control | 0.82 | −0.31 | −6.64 | PD_20_ FEV_1_ mean ± SD; median Pre-exposure:; 24.0 ± 15.7; 27.4; Postexposure:; 13.6 ± 20.5; 3.1; (p = 0.12)
| 40 minutes, 0 and 2,000 ppb [0, 2.46 mg/m^3^] | 2 ppm | −2.78 | 0.60 | −3.05 | PD_20_ FEV_1_ mean ± SD; median Pre-exposure:; 24.0 ± 15.7; 27.4; Postexposure:; 13.6 ± 20.5; 3.1; (p = 0.12)
| 40 minutes, 0 and 2,000 ppb [0, 2.46 mg/m^3^] | Similar patterns in exercise protocol. No decline in PEFR over 24 hours in either group. | | | | PD_20_ FEV_1_ mean ± SD; median Pre-exposure:; 24.0 ± 15.7; 27.4; Postexposure:; 13.6 ± 20.5; 3.1; (p = 0.12)
Harving et al. (1990); N = 15, ages 15–36, nonsmoking.; Design: Random assignment to exposure order (one per week); double blinded. Testing pre-exposure and near end of exposure period.; Evaluation^a^:; High confidence; Related Reference: Harving et al. (1986) | 90 minutes, filtered air (8), 0.120 and 0.850 mg/m^3^ | No difference in: | FEV_1_ | R_aw_ | SG_aw_ | No difference in challenge test:
| 90 minutes, filtered air (8), 0.120 and 0.850 mg/m^3^ | 0.008 mg/m^3^ | 100.9 | 2.21 | 10.67 | PC_20_ PEF
| 90 minutes, filtered air (8), 0.120 and 0.850 mg/m^3^ | 0.12 mg/m^3^ | 99.4 | 2.23 | 10.63 | 0.008 mg/m^3^ | 0.29
| 90 minutes, filtered air (8), 0.120 and 0.850 mg/m^3^ | 0.85 mg/m^3^ | 105.0 | 2.29 | 11.17 | 0.12 mg/m^3^ | 0.36
| 90 minutes, filtered air (8), 0.120 and 0.850 mg/m^3^ | 0.85 mg/m^3^ | 105.0 | 2.29 | 11.17 | 0.85 mg/m^3^ | 0.26
Green et al. (1987); n = 16, ages 19–35 years, nonsmoking.; Design: Two 15-minute exercise segments in 60-minute exposure period. Random assignment to order of exposure; single blinded. Testing pre- and during exposure period, ^~^15 minute intervals.; Evaluation^a^:; Medium confidence; Randomized, single blinded | 60 minute, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | No difference in FVC, FEV_1,_ SG_aw_, or other lung function measures | | | | No difference in challenge test:
| 60 minute, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | At 55 minutes | FVC | FEV_1_ | SG_aw_ | | PD_35_ SG_aw_
| 60 minute, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | Control | 4.62 | 3.54 | 0.114 | Control | 3.69
| 60 minute, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | 3 ppm | 4.56 | 3.46 | 0.111 | 3 ppm | 3.86
Sauder et al. (1987); n = 9, ages 26–40, nonsmoking.; Design: Clean air followed by formaldehyde (1 week apart); blinding of participant not specified. Testing during and at end of exposure.; Evaluation^a^:; Low confidence; Not randomized, blinding not specified | 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | No difference in FVC, FEV_1,_ SG_aw_, or other lung function measures. | | | | No difference in challenge test:
| 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | At 180 minutes | FVC | FEV_1_ | SG_aw_
| 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | Control | 4.11 | 3.02 | | | PD_35_ SGaw
| 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | | 0.101 | | | Control | 0.93
| 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | 3 ppm | 4.16 | 3.07 | | 3 ppm | 0.96
| 3 hours, clean air and 3,000 ppb [0, 3.69 mg/m^3^] | | 0.106
Krakowiak et al. (1998); n = 10, ages 23–52 years, some smokers, with occupational formaldehyde exposure; Design: Single blinded. Testing 2 hours pre-exposure and up to 24 hours after exposure.; Evaluation^a^:; Low confidence; Not randomized, single blinding, SE or SD not reported | 2 hours, 0.500 mg/m^3^ | No difference in FEV_1_ or PEF (mean values shown on graph; no indication of variability in measures) | | | | No difference in challenge test (PD_20_ FEV_1_) (mean values shown on graph; no indication of variability in measures)
Sheppard et al. (1984); n = 7, ages 18–37, nonsmoking; Design: Two protocols (at rest and during exercise). ≥1 day apart; blinding of participant not specified. Testing before and 2 minutes after exposure.; Evaluation^a^:; Low confidence; Not randomized, blinding not specified | 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | No difference between pre- and post SG_aw_^c^ in either protocol: | | | | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | Resting Exercise | | | | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | Control | −1.0 | | 1.8 | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | 1 ppm | 0.2 | | 2.2 | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | 3 ppm | NC | | 2.9 | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | | | | | Not assessed
| 10 minutes, 0, 1,000, and 3,000 ppb [0, 1.23, 3.69 mg/m^3^] | NC= not conducted | | | | Not assessed

Within each category, organized by study confidence, then descending publication year. Results for low confidence studies are shaded gray.

Abbreviations: Double blinded = investigator and participants unaware of which exposure; single blinded = participants were unaware of exposure. Late phase: between 4 and 6 hours after end of house dust mite bronchial challenge. PD_x_ = dose required to induce an x% reduction in the specified pulmonary function measure (i.e., PD_15_ FEV_1_ = dose required to induce a 15% reduction in FEV_1_); R_aw_ = airway resistance; SG_aw_ = specific airway conductance (corrected for lung volume); PEFR = peak expiratory flow rate.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.4).

b Witek et al. (1987) includes the same subjects as the Witek et al. (1986) paper, but with additional results presented in 1987.

c Postminus preexposure SG_aw_ (liters × cm H_2_O/liter); negative value indicates lower SG_aw_ postexposure.

##### Lower respiratory tract symptoms in infants and young children

Five studies (all medium confidence) examined other respiratory conditions in infants (followed up to age 18 months) and young children (age 6 months to 3 years); these studies focused on wheeze-relating symptoms, with or without accompanying lower respiratory tract infection (see Table 3-19). Li et al. (2019) is essentially a replication of Yu et al. (2017) in that it is conducted in the same area with the same study design but using a later birth cohort. These two studies are presented as a single entry in Table 3-19. Rumchev et al. (2002) is a study of emergency room visits for what was characterized as asthma (based on discharge diagnosis); information on the recruitment and selection process was not presented. The relatively young age of the children (mean 24 months, range 6 to 36 months) does not reflect the phenotypic expression of asthma, and thus this study likely represents wheezing episodes and various respiratory tract infections. Two 8-hour measures, in different seasons, of formaldehyde were taken in case and control homes; the length of time between the hospital visit and the study was not specified. Roda et al. (2011) was a follow-up of 2,940 infants in a birth cohort, with questionnaires regarding respiratory symptoms including lower respiratory infections and wheeze, completed by parents at 1, 3, 6, 9 and 12 months. Formaldehyde exposure was modeled based on housing characteristic data and the mean of four 1-week samples taken in homes at 1, 6, 9, and 12 months in a randomly selected subset of 196 homes. The sensitivity and specificity of the modeling was estimated as 72.4 and 73.6% respectively for categorization based on the median and 57.4 and 82.1% for categorization based on tertiles. EPA noted in its evaluation, however, that the modeling was not tested on a separate sample, and thus these model characteristic estimates may be high. Both of these studies reported associations between the examined outcome and residential formaldehyde levels, with effects seen above 0.020 mg/m^3^ in Roda et al. (2011) and above 0.060 mg/m^3^ (possibly above 0.050 mg/m^3^) in Rumchev et al. (2002). Another cohort study of infants used daily symptom diaries to assess wheezing episodes and did not see an association with formaldehyde at relatively low levels (OR 0.67, 95% CI: 0.29, 1.54, for exposures at 0.026 to 0.035 mg/m^3^ compared to 0.012 mg/m^3^) Raaschou-Nielsen et al. (2010). The two studies in Hong Kong were prospective studies of new-onset wheeze in infants. Both of these found increased risk of development of a first wheeze episode in relation to formaldehyde levels measured in the home. Li et al. (2019) Yu et al. (2017). The hazard ratio for time to first episode was 1.002 and 1.004 per 0.010 mg/m^3^ increase in formaldehyde at a mean level of 0.051 mg/m^3^. Although the conditions included in these studies do not fit within the usual classification of asthma, the observation of wheezing episodes at these early ages may have implications for subsequent disease risk, and in the case of Rumchev et al. (2002) (emergency room visits), also reflects an outcome with accompanying health care costs. The association of formaldehyde exposure with symptoms consistent with increased lower respiratory infections also may be indicative of immune suppression in the children, although this was not directly tested in the available studies, and mechanistic findings that may support these observations were similarly indirect and inconclusive (see Evidence on Mode-of-Action Section below). Although the congruence between the outcomes examined within these studies is not clear, the results of these studies indicate that the relationship between indoor formaldehyde exposure and respiratory conditions in infants and young children is an area requiring additional research.

Table 3-19 Lower respiratory tract conditions in infants and young children in relation to residential formaldehyde exposure

Study and design^a^ | Results
[Note: these two related studies were considered together; see below]; Li et al. (2019) (Hong Kong); Design: Prospective study of birth cohort (2013-2014), Infants aged <4 months (≥2.5 kg, gestation ≥36 weeks) followed to 18 months; n = 963 (67% of recruited) with outcome and exposure data.; Yu et al. (2017) (Hong Kong); Design: Prospective study of birth cohort (2009-2011), Infants aged <4 months, followed to 18 months; n = 535 (76% of recruited) with outcome and exposure data.; Exposure: Air sampling (NO_2_, formaldehyde), 72 hour samples at 6 months of age (concentrations not reported), ISAAC questionnaire included questions on environmental conditions in residence.; Exposure levels provided in Yu et al. (2017); Mean (SD) concentrations formaldehyde 0.051 (0.075) mg/m^3^; Outcome: Parent questionnaire (ISAAC) prior to 4 months, weekly respiratory health diary and monthly telephone survey to 18 months. New onset wheeze (time to event) measured from 6 to 18 months of age.; Evaluation:; Medium confidence; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. Authors did not respond to queries; EPA assumed exposure measurement details and exposure levels were similar in these two studies. | New onset wheeze; Li et al. (2019); Prevalence 12.5% at mean age of 13.4 months.; HR (95% CI) per 10 µg/m^3^; 1.002 (1.001,1.003)
| Cox proportional hazard models adjusted for NO_2_, sex, neo-natal respiratory illness, sibling, keeping pets, cooking fuel, and family history of non-asthma allergy or asthma.
| Yu et al. (2017); Prevalence 11% at mean age of 11.4 months.; Hazard Ratio (95% CI) per 10 µg/m^3^; 1.004 (1.001,1.007); Also adjusted for living area (ft^2^)
Roda et al. (2011) (France); Design: Prospective study of birth cohort, infants (singleton, >2,500 g) followed through age 1 year; n = 2,940 with 12-month questionnaire and formaldehyde measures (70% of 4,177 initial enrollees; 76% of those completing at least one questionnaire).; Exposure: Questionnaire on home characteristics at baseline and updated at 3, 6, 9 and 12 months.; N = 196 randomly selected for predictive modeling analysis; 4 1-week measures at 1, 6, 9 and 12 months. Predictive model used to assign subjects to categorical levels.; LOD 0.008 mg/m^3^. Median (25^th^, 75th percentile) 0.020 (0.014, 0.027) mg/m^3^. Exposure prediction model for high vs. low (based on median):; Exposure prediction model for high vs. low (based on median):; Sensitivity 72.4%; Specificity 73.6%; Exposure prediction model by tertile: Sensitivity 57.4%; Specificity 82.1%.; Outcome: Parent questionnaire at 1, 3, 6, 9, and 12 months used to define lower respiratory infections with and without wheeze; Evaluation^a^:; Medium confidence; Did not test predictive model on separate sample (may overestimate sensitivity and specificity) | OR (95% CI); [underlined: Lower respiratory tract infection] (Prevalence through age 1 year 45.8%); Per interquartile range increase:; 1.32 (1.11, 1.55); Above vs. below median (0.02 mg/m^3^):; 1.20 (1.03, 1.41); Top tertile vs. lowest tertile:; 1.31 (1.10, 1.57); [underlined: Lower respiratory tract infection with wheeze]; (Prevalence through age 1 year 22.3%); Per interquartile range increase:; 1.41 (1.14, 1.74); Above vs. below median (0.02 mg/m^3^); 1.31 (1.07, 1.59); Top tertile vs. lowest tertile:; 1.43 (1.14, 1.79); Adjusted for sex, prenatal and postnatal environmental tobacco smoke exposure, breastfeeding history, number of older siblings, day care attendance, furry pets in the home, humidity, parental history of asthma, and socioeconomic status.
Raaschou-Nielsen et al. (2010) (Denmark); Design: Prospective study of birth cohort, n = 343, infants of mothers with asthma (83% of 411 enrollees, 90% of 378 who participated through 18 months).; Exposure: 10-week samples in bedrooms, 1 to 3 sampling periods (at 6, 12, and 18 months of age). Analysis of variance: 31% between and 69% within person.; mean 0.020 mg/m^3^; median 0.018 mg/m^3^; 95th percentile 0.037 mg/m^3^; Outcome: Daily symptom diaries kept from birth to 18 months (reviewed at clinic visit every 6 months), recording of wheezing symptoms affecting activity or sleep.^b^; Evaluation^a^:; Medium confidence; Analysis does not take into account important features of the data (e.g., temporal variations in symptoms and large within individual variability in formaldehyde levels). | (n), OR (95% CI) by exposure quintiles. Outcome = any wheezing symptom day:
| <0.012 mg/m^3^ | (67) | 1.0 (referent)
| 0.012–0.016 | (69) | 1.11 (0.47, 2.63)
| 0.016–0.020 | (68) | 1.21 (0.51. 2.92)
| 0.020–0.026 | (71) | 1.40 (0.57, 3.47)
| >0.026 | (68) | 0.67 (0.29, 1.54) (trend p = 0.49)
| Adjusted for sex, area of residence, education of mother and log transformed baseline lung function
Rumchev et al. (2002) (Australia); Design: Case-control study, n = 88 cases, n = 104 controls (health department); ages 6 months to 3 years (mean 25 months for cases, 20 months for controls). Participation rates not reported.; Exposure: Two 8-hour measures (winter, summer) in home (living room, bedroom); mean (max) (mg/m^3^); living room: 0.028 ((0.189); bedroom: 0.030 0.244); Outcome: Emergency room discharge diagnosis of asthma; Evaluation^a^:; Medium confidence; Recruitment process not described; uncertainty as to what is included within this case definition and length of time between emergency room visit and subsequent exposure measure.; Related References: Rumchev et al. (2004) | OR (95% CI) by exposure category^b^:
| Emergency room discharge diagnosis of asthma
| 0.010–0.029 mg/m^3^ | 0.95 (0.8, 1.1)
| 0.030–0.049 | 0.95 (0.8, 1.2)
| 0.050–0.059 | 1.2 (0.9, 1.6)
| ≥0.060 | 1.39 (1.1, 1.7)
| Per 0.010 mg/m^3^: 1.003 (1.002, 1.004)
| (OR and 95% CI for all categories except ≥0.060 mg/m^3^ estimated from figure in the paper; numbers in each exposure were not reported)
| Adjusted for age, sex, allergic sensitization to common allergens, family history of asthma, relative humidity, indoor temperature, socioeconomic status, pets, air conditioning, gas appliances, smoking inside, house dust mite levels

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see Appendix B.3.4).

##### Susceptibility: modifying factors affecting prevalence of asthma or allergic sensitization

Asthma and atopic sensitization are hypothesized to be affected by a combination of genetic and environmental factors. Several sensitization and asthma studies included analyses pertaining to effect modification by factors that may help elucidate pathogenesis and susceptibility, such as atopy. In the study of adult women by Matsunaga et al. (2008), the association between use of medication for atopic eczema and formaldehyde exposure was stronger among women with no family history of allergy (OR 2.96, 95% CI 0.87, 10.12) than among women with a family history of allergy (OR 1.63, 95% CI 0.58, 4.57) at exposures of 0.058 to 0.161 mg/m^3^ compared with <0.058 mg/m^3^. The pattern across exposure levels also revealed an increase in risk of atopic eczema at lower exposures in the negative family history group (OR 1.37, 1.88, and 4.21) compared with the positive family history group (OR 0.80, 0.92, and 1.45) (see Figure 3-11A). The pattern is difficult to interpret in the study by Annesi-Maesano et al. (2012) (see Figure 3-11 B), as an indication of effect modification at lower exposures was not seen at higher exposures. Note that the direction of effect modification seen in Matsunaga et al. (2008) differs from that described in the preceding section (i.e., the stronger association between formaldehyde and asthma control among children with atopy compared to nonatopics in Venn et al. (2003). Examination of the presence of interactions and the factors contributing to them requires large studies designed to test specific hypotheses defined a priori; thus, additional research is needed to address the question of potential effect modification of atopic eczema or asthma symptom prevalence by atopy status.

Tobacco smoke represents an environmental factor that may increase the incidence of hypersensitivity responses in formaldehyde-exposed individuals. Two studies included IgE or asthma analyses stratified by environmental tobacco smoke exposure among children and adults (nonsmokers) (Palczynski et al., 1999; Krzyzanowski et al., 1990). There was some evidence of effect modification by environmental tobacco smoke (i.e., stronger associations, or associations seen at lower formaldehyde exposures, seen with this coexposure). In the Palczynski et al. (1999) study, there was no association between formaldehyde and either IgE levels or asthma prevalence in the full sample of children or of adults. Analyses stratified by the presence of environmental tobacco smoke exposure in the home, however, indicated associations between formaldehyde (at levels of 0.025−0.050 mg/m^3^) and (1) elevated IgE in children (but not adults), and (2) asthma in adults (but not in children). In the study by Krzyzanowski et al. (1990), an association between formaldehyde and asthma was seen in children exposed to environmental tobacco smoke, but evidence of this type of effect modification was not seen in adults (see Table 3-20). Additional studies are needed to establish if this interaction is seen only in children, only in adults, in adults and children, or in neither group.

Figure 3-11 Examination of effect modification by family or personal history of atopy

(A) Relative risk of prevalence of atopic eczema in adults (Matsunaga et al., 2008). Family history defined as parent or sibling with doctor-diagnosed asthma, atopic eczema, or allergic rhinitis. (B) Relative risk of prevalence of asthma in children (Annesi-Maesano et al., 2012). Atopy based on positive skin prick test (10 allergens).

Table 3-20 Effect modification by environmental tobacco smoke: results from studies in children and adults

Study and design^a^ | | Results
Palczynski et al. (1999) (Poland); Design: Prevalence study, n = 278, ages 16–65 and n = 187, ages 5–15 years from 120 households with children (random selection, 10-year old apartments).; Participation rate not reported.; Exposure: 24-hour household sample (area not specified); Mean (±SD) (minimum, maximum) 0.026 (±0.011); (0.002, 0.067) mg/m^3^; 2% >0.050 mg/m^3^; Outcome: Bronchial asthma diagnosed using American Thoracic Society criteria.; Evaluation^a^:; Medium confidence; Uncertainty regarding asthma definition. Not informative above 0.050 mg/m^3^ because of sample size (n = 4). | | | N per group (Percentage with Current Asthma)
| | | Environmental Tobacco Smoke
| | Exposure (mg/m^3^) | Positive | Negative
| | Children, IgE >100 kU/L
| | <0.025 | 39 (38.5) | 55 (29.1)
| | 0.025–0.050 | 44 (52.3) | 46 (23.9)
| | 0.051–0.067 | 2 (0.0) | 1 (100.0)
| | (Fisher’s exact test p-value, children) | (0.005)
| | Adults, IgE >100 kU/L
| | <0.025 | 34 (23.5) | 67 (29.9)
| | 0.025–0.050 | 36 (22.2) | 57 (26.3)
| | 0.051–0.067 | 2 (0.0) | 2 (0.0)
| | Children, Asthma
| | <0.025 | 39 (6.9) | 55 (5.4)
| | 0.025–0.050 | 44 (2.3) | 46 (6.5)
| | 0.051–0.067 | 2 (0.0) | 1 (0.0)
| | Adults, Asthma
| | <0.025 | 34 (5.9) | 67 (4.4)
| | 0.025–0.050 | 36 (13.9) | 57 (1.8)
| | 0.051–0.067 | 2 (0.0) | 2 (0.0)
| | (Fisher’s exact test p-value, adults) | (0.03)
Krzyzanowski et al. (1990) (United States, Arizona); Design: Prevalence study, adults (n = 613 ages >15, mean 37) and children (n = 298 ages 5–15, mean 9.3) from 202 households (stratified sample from municipal employees). Participation rate not reported. 67% whites; Exposure: Two one-week samples (opposite seasons) in kitchen, living area, and bedroom (converted from ppb). Household: mean 0.032 mg/m^3^ | | | N per group (Percentage with Current Asthma)
| | Children | Environmental Tobacco Smoke
| | Exposure (mg/m^3^) | Positive | Negative
| | <0.049 | 106 (15.1) | 142 (8.5)
| | 0.049–0.074 | 12 (0.0) | 12 (8.3)
| | >0.074–0.172 | 11 (45.5) | 10 (0.0)
| | (trend p-value) | (<0.05) | (>0.50)
<0.049 mg/m^3^ | 83.7%
0.049–0.074 | 10.0% | Log-linear models, stratified by environmental tobacco smoke, adjusted for socioeconomic status, ethnicity.
>0.074–0.172 | 6.3% | Adults: Results reported as “not significantly related” but rate of wheeze was “somewhat higher” with higher exposure; analyses stratified by environmental tobacco smoke exposure not reported.
Only a few values above 0.111 mg/m^3^.; Outcome: Current asthma (doctor diagnosed) and asthma symptoms based on American Thoracic Society questionnaire (physician diagnosed) Ferris (1978).; Evaluation^a^:; Medium confidence or children, relatively small n in higher exposure categories; for adults, incomplete reporting.; Related references: Quackenboss et al. (1989a); Quackenboss et al. (1989c) | | Adults: Results reported as “not significantly related” but rate of wheeze was “somewhat higher” with higher exposure; analyses stratified by environmental tobacco smoke exposure not reported.

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see Appendix B.3.4).

##### Summary of Human Evidence Synthesis Judgments on Immune-Mediated Conditions

###### Allergic Conditions

The following factors, in particular the consistency, strength, and precision were influential to the synthesis judgment that the human studies of allergic conditions provide moderate evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence Among the seven high or medium confidence studies in residential and school settings, elevated risks for at least one of the allergy-related conditions examined (symptoms relating to nose, eyes, or skin) at exposures around 0.04 mg/m^3^ and above were seen. These studies were conducted in 6 different countries in Europe and Asia, using a variety of study designs that were considered appropriate by the expert panel consulted by EPA.
- Biological Gradient: An exposure-response gradient was seen across categories of disease severity, and in the studies of rhinoconjunctivitis in children and eczema in adults that examined multiple exposure categories.
- Strength and Precision: The effect size was relatively small for rhinitis and rhinoconjunctivitis (RR around 1.2); stronger effects were seen in the only study of eczema in adults, and in a study examining the combination of symptoms involving eyes, nose, and skin.

###### Asthma

The consistent and strong magnitude of effects at formaldehyde levels > 0.05 mg/m^3^ were most influential to the synthesis judgment that the human studies of the prevalence of current asthma provide moderate evidence of formaldehyde exposure-induced effects.

- Consistency and Biological Gradient: The five medium or high confidence studies at exposures of ≤0.050 mg/m^3^ do not indicate risk at these lower exposure levels. In contrast, seven residential or school studies with higher exposure levels reported an elevated risk for asthma, beginning around exposure levels of 0.05 mg/m^3^ formaldehyde, with most of these risk ratios around 2.0 for children. Two studies with relatively high exposures included both children and adults (Zhai et al., 2013; Krzyzanowski et al., 1990), and each provides evidence of a greater susceptibility in children. The set of high or medium confidence studies in residential and school settings were conducted in the United States, Europe, and Asia, and used a variety of study designs that were considered appropriate by the expert panel consulted by EPA. In addition, the three medium confidence occupational studies at higher formaldehyde levels similarly observed increased risk, with relative risk estimates between 1.5 and 5.5 for exposures ranging from 0.1 mg/m^3^ to > 0.5 mg/m^3^ formaldehyde.
- Strength and Precision: Large elevations in risk were observed in three medium confidence occupational studies; the summary RR for the high-exposure (> 0.1 mg/m^3^) occupational studies was 3.79 (95% CI 1.98, 7.28). These findings were supported by smaller (around 2-fold) elevations across residential- and school-based exposure studies above 0.05 mg/m^3^.
- Coherence: The two medium or high confidence studies of control of asthma symptoms provide additional support for the effects of formaldehyde exposure among children with asthma at levels at or below those seen in the studies of formaldehyde in relation to the prevalence of asthma. This effect on symptom control is further supported by indirect evidence from a randomized controlled trial designed to improve ventilation rates and thus reduce exposure to formaldehyde and other indoor air pollutants; although levels of formaldehyde showed the largest decline in this study, it is not possible to solely attribute the improvements seen in symptoms control to formaldehyde.
  The studies of wheezing episodes in infants, particularly the birth cohort studies, are not classified as studies of asthma per se, but could be indicative of respiratory effects with implications for subsequent disease risk. Thus, the associations seen between residential formaldehyde exposure above 0.50 mg/m^3^ and frequency or onset of first wheezing event in these studies provides further support for the relevance of the body of evidence relating to asthma.

#### Animal Studies

The animal studies most relevant to evaluating potential effects on allergy-related conditions and asthma, as well as a single study suggesting a potential increased vulnerability to respiratory infections, are discussed in the sections below.

##### Allergy-related conditions and asthma

There are currently no universally accepted animal models applicable to humans for determining dose-response relationships or the potency of low molecular weight chemicals to induce allergic symptoms via the inhalation route (IPCS, 2012). The majority of the experimental animal formaldehyde studies that are most relevant to interpreting these respiratory immune-mediated conditions used the ovalbumin (OVA) murine model, the best studied animal model of asthma. However, the OVA mouse model has several limitations relative to human data for hazard characterization. They include the following:

- Key features of human asthma are absent or minimal in the OVA model, including a lack of airway remodeling (Shin et al., 2009) and minimal airway hyperreactivity and eosinophilic inflammation (Mullane and Williams, 2014)
- OVA challenge models a small subset of endpoints and genes compared with those in humans (Mullane and Williams, 2014)
- The OVA model elicits an acute disease in contrast to the chronic condition in humans (Shin et al., 2009), and the antigen ovalbumin has questionable relevance and poor translatability for human asthma (Mullane and Williams, 2014; Bates et al., 2009)
- A standardized method for OVA administration is lacking; this precludes comparing results between laboratories and evaluating study protocols (Bates et al., 2009)
- There is uncertainty regarding the biological significance of airway hyperreactivity in mice (Bates et al., 2009)

In light of these limitations, EPA concluded for this assessment that the OVA model was more appropriate for examining mechanistic questions in support of hazard identification, based in part on the reasonably large number of well-conducted human studies on these endpoints. As such, the experimental animal studies were considered to be less informative than human studies for drawing interpretations regarding the potential for formaldehyde inhalation exposure to induce or exacerbate allergy-related conditions or asthma, and these studies are discussed below as mechanistic information that may add insight to the apical effects observed in exposed humans.

##### Other respiratory conditions

One experimental animal study of medium or high confidence evaluated endpoints related to the potential for formaldehyde exposure to cause other immune-mediated respiratory conditions and reported a decrease in pulmonary antibacterial activity in mice exposed to 1.23 mg/m^3^ formaldehyde for less than 1 day (Jakab, 1992). While such a finding could indirectly suggest that formaldehyde exposure might predispose animals to developing lower respiratory infections, this hypothesis was not specifically tested and other notable uncertainties with the study design exist (see Appendix B.3.6). Animal studies of long-term duration that are specifically designed to examine the functional capacity of the respiratory immune response would be informative.

##### Summary of Animal Evidence Synthesis Judgments

As described above, the available animal studies most relevant to evaluating potential effects on allergy-related conditions and asthma were ultimately considered as mechanistic information rather than as an independent line of evidence. Taken together with the other available mechanistic information (see below), the available data are interpreted to provide slight animal evidence for an effect of formaldehyde inhalation on both allergic conditions and the prevalence of current asthma.

#### Evidence on Mode of Action

An integrated evaluation of the abundant mechanistic information that might be relevant to the potential development of immune-mediated conditions following formaldehyde inhalation exposure is described in Appendix C.7, including evaluations of the individual mechanistic studies (Appendix B.3.6). The evaluation includes the somewhat heterogeneous data related (either directly or indirectly) to possible increases in respiratory infections after exposure, although those data are not discussed in detail in this section. Thus, this discussion focuses on mechanistic information that may inform the potential for formaldehyde to affect allergic conditions or asthma. This includes animal models using the allergen, OVA, which, although they do not fully capture the phenotype of human asthma or allergy-related conditions, can provide insight into some of the mechanistic changes that are relevant to these human conditions.

As shown in Figure 3-12, the integrated analysis identified three pathways describing potential associations between the most relevant mechanistic data available, with several of the initial or early events in these hypothesized pathways (e.g., oxidative stress and molecular or cellular inflammatory changes) generally observed to occur at lower formaldehyde levels than other downstream changes (see Table 3-21). Overall, the mechanistic support for airway inflammation-induced hyperresponsiveness was stronger than for the other potential pathways (i.e., based primarily on moderate evidence of mechanistic events and their relationships). Although a definitive MOA(s) could not be defined, and it is unclear whether some important events would occur with chronic low-level formaldehyde exposure, the data were interpreted to identify an incomplete mechanism(s) by which formaldehyde exposure could cause this effect (see Figure 3-12), providing biological plausibility for inflammatory airway changes that could contribute to respiratory immune-mediated conditions. The mechanistic support for allergic sensitization was less clear (i.e., based on some potentially relevant events interpreted with moderate evidence and, in general, slight evidence for the relationships between events), because reliable data identifying mechanistic changes typically thought to be essential for sensitization, including changes in IgE, were lacking. However, moderate evidence for several mechanistic changes relevant to these responses was identified, providing some biological support. Importantly, while many individual mechanistic events observed in animals are considered to be relevant to interpreting changes that may occur in the human airways, including potentially amplified responses to inhaled materials, it is unclear how translatable these pathways are to interpreting complex human diseases like asthma, and notable key events have not been observed. Some of the data most informative to drawing conclusions for these health endpoints are described in greater detail below (see Tables 3-21 and 3-22).

Figure 3-12 Possible mechanistic associations between formaldehyde exposure and immune-mediated conditions, including allergies and asthma

An evaluation of the formaldehyde exposure-specific mechanistic evidence informing the potential for formaldehyde exposure to cause respiratory health effects (see Tables 3-21 and 3-22, and Appendix C.7) identified these mechanistic pathways as most relevant to interpreting effects on respiratory immune-related conditions such as asthma and allergic responses. Similar to effects on pulmonary function, events related to indirect stimulation of lower respiratory tract (LRT) sensory nerve endings (top pathway) were considered as likely to represent an incomplete mechanism by which formaldehyde inhalation could cause airway hyperresponsiveness, although whether certain events occur with chronic, low-level exposure remains unclear. While the observed alterations to circulating antibodies (i.e., primarily related to IgG and not IgE) following formaldehyde exposure might contribute to the development of both allergic sensitization and airway hyperresponsiveness (middle pathway), in the absence of additional clarifying data, this could not be identified as a likely mechanism for these effects. Likewise, the slight evidence of altered T cell-related airway responses and, secondarily, inflammatory eosinophil responses might be useful for explaining allergic sensitization (bottom pathway) if additional data were available to better explain the pattern and strength of these associations. Conversely, sustained airway inflammation, at least in animals previously sensitized to an allergen, was interpreted as likely to be an incomplete explanatory mechanism for airway hyperresponsiveness, although the sequence of events leading to inflammation remain unclear. Interdependencies between the top and bottom pathways are likely to exist for airway hyperresponsiveness.

It is informative to consider the formaldehyde-specific mechanistic information in the context of the known pathogenesis of human asthma and related conditions. Asthmatic airways are characterized by an infiltration of eosinophils, plasma B cells, activated mast cells, and T cells that contribute to thickening of the airway wall, mucous secretion, airway remodeling, and airway hyperresponsiveness. Initiation and perpetuation of asthma are believed to be the result of T_H_2 activity (Cohn et al., 2004). Specifically, T_H_2 cells accumulate in the airway and secrete cytokines IL-4 and IL-13, which stimulate B cells to produce IgE (Barnes, 2008) (see Figure 3-13). Mast cells bind IgE and display this immunoglobulin as an allergen-specific receptor on their surfaces. When an allergen binds to this IgE, the mast cell is activated, triggering its release of several bronchoconstrictors (e.g., histamine, leukotrienes), which drive the disease state. T_H_2 cells also release IL-5 that activates eosinophils following their migration into the airways. The precise role of eosinophils in asthma is unknown, but they are thought to contribute to inflammation (Barnes, 2008). Immune function and inflammatory responses do not fully explain the pathogenesis of asthma, particularly with respect to the varying phenotypes seen at a clinical level (Anderson, 2008). The interaction between nerve cells and the immune system also includes evidence that neuropeptide release may contribute to neurogenic inflammation and heightened airway responsiveness (Veres et al., 2009).

Figure 3-13 Inflammatory and immune cells involved in asthma

Inhaled allergens activate sensitized mast cells by crosslinking surface-bound IgE molecules to release prostaglandin D2. Epithelial cells release stem-cell factor (SCF), which is important for dendritic cells, which are conditioned by thymic stromal lymphopoietin (TSLP) secreted by epithelial cells and mast cells to release the chemokines CC-chemokine ligand 17 (CCL17) and CCL22, which act on CC-chemokine receptor 4 (CCR4) to attract T-helper 2 (T_H_2) cells. T_H_2 cells have a central role in orchestrating the inflammatory response in allergy through the release of interleukin-4 (IL-4) and IL-13 (which stimulate B cells to synthesize IgE), IL-5 (which is necessary for eosinophilic inflammation), and Il-9 (which stimulates mast-cell proliferation). Epithelial cells release CCL11, which recruits eosinophils via CCR3. Patients with asthma may have a defect in regulatory T (T_reg_) cells, which may favor further T_H_2-cell proliferation. Reprinted from Barnes (2008) with permission from Nature Publishing Group.

The mechanistic evidence that provides the most direct information regarding the potential role of formaldehyde in respiratory hypersensitivity responses consists of five high or medium confidence studies, some of which appeared to study the same animals (Swiecichowski et al., 1993; Riedel et al., 1996; Larsen et al., 2013; Ito et al., 1996; Fujimaki et al., 2004b).^20^ These studies all differed in the conditions under which formaldehyde affected asthma-relevant endpoints, specifically increased bronchoconstriction and airway hyperresponsiveness, using short-term and acute exposures in sensitized and nonsensitized animals. Formaldehyde exposure of 0.369 to 36.9 mg/m^3^ increased bronchoconstriction in guinea pigs exposed for 2 to 8 hours (Swiecichowski et al., 1993). Both the in vivo and ex vivo data from this study indicate that smooth muscle airways are a (presumably indirect) target for formaldehyde. A 5-day formaldehyde exposure of 0.31 mg/m^3^ prior to OVA sensitization increased OVA-induced bronchoconstriction in guinea pigs, indicating that formaldehyde exposure enhances reactivity to OVA sensitization (Riedel et al., 1996). Finally, a single 60-minute formaldehyde exposure of 7.0 mg/m^3^ induced bronchoconstriction in OVA-sensitized mice housed only in humid, but not dry, environments, indicating that the bronchoconstrictive effects of formaldehyde may be impacted by humidity (Larsen et al., 2013). Taken together with supportive findings from a number of low confidence human and animal studies (see Appendix C.7, with study evaluation documentation in Appendix B.3.6), results across multiple species indicate that formaldehyde exposure is sufficient to trigger bronchoconstriction in both sensitized and nonsensitized animals, and that exposure appears to result in the development of hyperresponsive airways,^21^ particularly in sensitized animals. This finding is consistent with the evidence supporting increases in microvascular leakage, edema, and other inflammatory airway changes with formaldehyde exposure after allergen sensitization (see Section 3.2.2 and Appendix C.7). Overall, the data do not indicate that formaldehyde is itself immunogenic, but instead suggest formaldehyde may augment immune responses to other allergens.

Other findings that may be relevant to asthma or allergic conditions with at least a moderate level of evidence include increases in airway eosinophils, increases in protein mediators of bronchoconstriction such as tachykinins, and changes in antibody titers (see Section 3.2.2 and Table 3-21). Although a precise role for eosinophils in asthma is unknown (i.e., eosinophilia is not necessary for the development of asthma), eosinophilic airway inflammation (presumably mediated by T_H_2 lymphocytes) is a hallmark of asthma (George and Brightling, 2016); the formaldehyde-specific evidence supports that eosinophils are increased in both the upper and lower airways following formaldehyde exposure, particularly with allergen sensitization (see Section 3.2.2). As activation of eosinophils can induce airway hyperresponsiveness and perpetuate further recruitment of inflammatory mediators into the airway (Cohn et al., 2004), these changes provide coherent biological support for the more apical immune-mediated conditions. In addition, as previously discussed (see Section 3.2.2), it appears that formaldehyde exposure mediates (at least in part) lung inflammation via tachykinins in rats and mice. For example, high or medium confidence studies show that substance P, a tachykinin and NK1 ligand, is dose-dependently increased in mice exposed for 12 weeks to 0.1 to 2.5 mg/m^3^ formaldehyde (Fujimaki et al., 2004b), and that an antagonist of the NK1 receptor can completely abrogate formaldehyde-induced airway inflammation, at least following a 10-minute formaldehyde exposure at 18 mg/m^3^ (Ito et al., 1996). Somewhat surprisingly, however, the formaldehyde-induced increases in substance P observed by Fujimaki et al. (2004b) were not observed in animals sensitized to OVA, despite the observation that airway eosinophils were increased at 2.5 mg/m^3^ formaldehyde only in animals that were sensitized. Thus, some uncertainties remain. The results related to antibody production, although providing moderate evidence of an effect, were difficult to interpret in the context of their relevance to asthma. Specifically, while evidence from human and animal studies suggests that formaldehyde exposure modifies antibody responses, the most consistently observed responses were associated with changes in IgG, not IgE (see Table 3-21). The relevance of IgG-related responses to asthma or allergies is unclear.

Several other airway changes relevant to asthma or allergic conditions were not supported by moderate or robust evidence in the available studies. For example, slight evidence supports changes in CD8^+^ T cells or asthma-relevant T_H_2 cytokines, including IL-4 [and, to a lesser extent, IL-5 and RANTES (regulated on activation, normal T cell expressed and secreted)], in the lungs after exposure to 0.5−12 mg/m^3^ formaldehyde in both sensitized and nonsensitized rodents; however, no changes in IL-13 or histamine have been reported. At the cellular level, while slight evidence supports that CD8^+^ T cells might be increased in naïve rodents exposed to >7 mg/m^3^ formaldehyde, mast cells or other T cell populations did not appear to be changed in the few studies that examined them, and none of the identified studies investigated other cells of interest (e.g., dendritic cells, smooth muscle cells).

Immune-related changes in the blood may also be relevant to interpreting the development of allergic conditions, and possibly asthma, albeit indirectly. A number of studies, across different human and animal populations, spanning an array of formaldehyde exposure scenarios, have reported changes in blood cell counts and secreted factors (see Table 3-22). Although some of the specific changes vary across studies, taken together, the data provide robust evidence of an association between formaldehyde exposure and hematological effects. Interestingly, some changes noted in the blood of individuals exposed to formaldehyde are contrary to the cellular changes noted in the respiratory tract (e.g., CD8^+^ T cells appear to be increased in the respiratory tract and decreased in the blood) (see additional discussion in Appendix C.7). Potential explanations could include recruitment of subsets of immunoresponsive cells from the circulation to the irritated and inflamed respiratory tract (e.g., due to a gradient of chemoattractants or other factors across tissue compartments, potentially resulting from sustained airway inflammation), or species differences in responses (i.e., LRT data are mostly from animal studies, while the data in blood are primarily from humans); however, none of the identified human studies report data across tissue compartments, and the animal data do not address such hypotheses. Overall, similar to the cellular changes in the LRT, no explanation exists for how formaldehyde exposure could affect blood immune cell counts.

One of the most consistent blood cell changes observed across studies was a decrease in the total number of white blood cells (WBCs), including moderate evidence of CD8^+^ T cell decreases following formaldehyde exposure and a corresponding increase in the ratio of CD4^+^/CD8^+^ T cells (see Table 3-22). Depending on the specific stimuli, stimulated CD8^+^ T cells can produce interferon-γ (IFN-γ) and inhibit production of IL-4 and immunoglobulin (i.e., IgE) responses (Holmes et al., 1997), or their phenotype can be driven toward production of excess IL-4, a situation hypothesized to be associated with atopic asthma (Lourenço et al., 2016). IL-4 can stimulate T cell receptors on CD4^+^ and CD8^+^ T cells (Serre et al., 2010), and can both drive CD4^+^ T cells toward a T_H_2 response (Kopf et al., 1993) and influence the activation and development of antigen-specific CD8^+^ T cell immunity by shifting the phenotype of these cells from IFN-γ production to IL-4 production (Erb and Le Gros, 1996). Moderate evidence provides support for increases in blood IL-4 (slight evidence supports similar increases in the LRT) and decreases in IFN-γ after formaldehyde exposure. Interestingly, several lines of evidence suggest a pattern of immune cell effects related to formaldehyde concentration, with potential stimulation at lower formaldehyde exposure levels and decreases at higher levels. This included slight evidence of changes in total T cells, NK cells, and IL-10. A complex relationship exists between IL-10, NK cells, and subsets of CD4^+^ T cells (e.g., T_H_1 and T_H_2 cells), which can affect antibody responses (Moore et al., 2001). However, the potential effects of formaldehyde exposure on the specific phenotype of CD4+ or CD8+ T cells, or on the relationship between changes in lymphocyte populations or secreted factors and respiratory hypersensitivity, have not been well studied and remain to be elucidated.

Several other changes in the blood are of interest to the development of immune-mediated conditions (see Appendix C.7 for additional discussion). Moderate evidence supports that formaldehyde exposure alters the percentage of B cells in the circulation. These cells produce antibodies upon stimulation with antigen (e.g., allergens) and can contribute to airway hyperresponsiveness (Hamelmann et al., 1997). While this finding, along with slight evidence of increased antigenic markers, suggests the potential for alteration of the adaptive immune response after formaldehyde exposure, this observation alone is insufficient to indicate functional changes such as exposure-induced differences in clonal expansion and differentiation to antibody-producing cells, evidence of which would support a more convincing biological relationship. In addition, red blood cell counts were decreased in both human and animal studies (moderate evidence), generally at formaldehyde concentrations above 0.5 mg/m^3^, although the relevance of these changes to respiratory system health effects is unknown. It is plausible that sustained increases in oxidative stress (markers for which are consistently elevated in blood and respiratory tissues after formaldehyde exposure), or other soluble factors that could result from airway inflammation, might affect the viability of circulating erythrocytes and immune cells, or the circulating precursors for these cells; however, no evidence exists to substantiate this hypothesis. An increased level of the circulating stress hormone, corticosterone (the major animal glucocorticoid; in humans, it is cortisol), with short-term, but not acute, formaldehyde exposure is also suggested. Persistent increases in circulating glucocorticoids can also negatively impact the function and health of circulating immune cells, causing immunosuppression of most cell types (O’Connor et al., 2000). However, these potential linkages have also not been examined.

Overall, although additional studies clarifying inconsistencies across the studies would be informative, the available data support a conclusion that formaldehyde exposure can modify immune system function in the blood across a range of concentrations and exposure durations. Many of these observations would benefit from more specific studies on WBCs focused on understanding the phenotype of the modified cells, and the profile of secreted factors in the blood, particularly after formaldehyde exposures of varying duration and concentration. Taken together, the available mechanistic studies provide consistent evidence that formaldehyde may stimulate a number of immunological and neurological processes related to allergic or asthmatic responses; however, a molecular understanding of how formaldehyde exposure might favor asthmatic T_H_2 responses has not been established and additional experimental support is necessary to interpret the translatability of these pathways to complex human airway diseases such as asthma. Importantly, the evidence supports that formaldehyde exposure induces bronchoconstriction with and without allergen sensitization, providing strong biological support for the development of hyperresponsive airways that could contribute to at least some of the observed respiratory immune-related symptoms. This heightened bronchoconstriction response may be due to a combination of neurogenic mechanisms through reduction of anti-inflammatory molecules or increased tachykinins, increased T_H_2 cytokines and antibodies, and eosinophil recruitment and activation in the lung. Immune- and inflammatory-related changes in the blood provide additional support for exposure-induced alterations relevant to the development of these immune-mediated conditions. Additional studies are necessary to clarify the incomplete understanding of mechanisms that describe the association between formaldehyde exposure and these effects, as well as the exposure concentration and duration dependence of some of the more influential findings from the current studies. Collectively, the available studies provide mechanistic support for the biological plausibility of the formaldehyde exposure-induced changes observed in humans.

Table 3-21 Mechanistic evidence most informative to the development of immune-mediated conditions after formaldehyde inhalation^a^

Endpoint | Endpoint-specific findings and confidence | | Summary of evidence | Conclusion
Modifications in the upper or lower respiratory tract (URT or LRT)
Some of these mechanistic changes have been discussed in previous sections.; See Section 3.2.2, Evidence on Mode of Action, for presentation of the evidence for:; ↑ LRT oxidative stress (moderate); LRT sensory nerve activation (slight); ↑ LRT neuropeptides (moderate); ↑ LRT microvascular leakage (moderate); ↑ LRT eosinophils (moderate); ↑ airway edema or other inflammatory structural change; and URT epithelial damage (robust)
Upper airway indicators of altered immune function (inferred from URT infections) | High or Medium | Human: Increased frequency and duration of URT infections in symptomatic workers; increased chronic URT inflammation (and decreased function of blood neutrophils, but N/C in leukocyte counts) in exposed workers (Lyapina et al., 2004): chronic (years) exposure at 0.87 mg/m^3^ (Note: recent URT infection was often an exclusion criterion in observational studies focusing on pulmonary function) | Indirect evidence of decreased immune capacity in a human study of longterm exposure at 0.87 mg/m^3^ (note: mRNA changes were not necessarily indicative of a decreased immune response) | Slight; (indirect evidence of ↑URT infection)
Upper airway indicators of altered immune function (inferred from URT infections) | | Animal: mRNA changes suggestive of altered immune response (Andersen et al., 2010): short-term (≥1 week) exposure at ≥12.3 mg/m^3^ | Indirect evidence of decreased immune capacity in a human study of longterm exposure at 0.87 mg/m^3^ (note: mRNA changes were not necessarily indicative of a decreased immune response)
Upper airway indicators of altered immune function (inferred from URT infections) | Low | Human: None | No evidence to evaluate
Upper airway indicators of altered immune function (inferred from URT infections) | Low | Animal: None | No evidence to evaluate
Lower airway indicators of altered immune function (inferred from LRT infections) | High or Medium | Human: Increased LRT infections in infants (Roda et al., 2011): 32–41% increase in incidence per 0.0124 mg/m^3^ increase in formaldehyde (LOD: 0.008 mg/m^3^); ^~^1-year exposure at 0.020 mg/m^3^ (median) | Indirect evidence in a single study of infants exposed to a median of 0.020 mg/m^3^ observing an association between exposure and increased infections. One acute mouse study also provided indirect support for an increased likelihood of respiratory infections. | Moderate; (indirect support for an increased propensity for LRT infections, particularly during development)
Lower airway indicators of altered immune function (inferred from LRT infections) | High or Medium | Animal: Decreased antibacterial activity in mice (Jakab, 1992): acute exposure at 1.23 mg/m^3^, noting that this finding appeared to be particularly sensitive to the pattern of formaldehyde exposure | | Moderate; (indirect support for an increased propensity for LRT infections, particularly during development)
Lower airway indicators of altered immune function (inferred from LRT infections) | Low | Human: Increased emergency room visits for episodes including LRT infections (Rumchev et al., 2002): children aged 6–36 months at mean levels 0.028–0.030 mg/m^3^ (maximum 0.12–0.22) | Direct and indirect evidence of impaired LRT immune function in children and in a short-term rat study, respectively | Moderate; (indirect support for an increased propensity for LRT infections, particularly during development)
Lower airway indicators of altered immune function (inferred from LRT infections) | Low | Animal: Decreased expression of immune-related genes in rat lung (Sul et al., 2007), specifically HSP701a (involved in antigen presentation), complement four binding protein (binds necrotic or apoptotic cells for cleanup), and Fc portion of IgGiii (involved in leukocyte activation): 2 week exposure at ≥6.15 mg/m^3^ | Direct and indirect evidence of impaired LRT immune function in children and in a short-term rat study, respectively | Moderate; (indirect support for an increased propensity for LRT infections, particularly during development)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictor allergen) (Note: unprovoked responses are not included) | High or Medium | Human: None | Acute and short-term studies in two animal species demonstrate that formaldehyde increases responsiveness to allergens and bronchoconstrictors, particularly with prior sensitization, at levels as low as 0.31 mg/m^3^ | Robust; (↑ Hyperresponsive airways^b^)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictor allergen) (Note: unprovoked responses are not included) | High or Medium | Animal: [allergen challenge]: With ovalbumin [OVA] sensitization, increased airway obstruction in guinea pigs (Riedel et al., 1996): short-term exposure at 0.31 mg/m^3^ and increased reactivity in mice (Larsen et al., 2013): acute exposure at ^~^5–7 mg/m^3^ in humid or dry environments; [acetylcholine challenge]: Increased airway resistance and reactivity in guinea pigs (Swiecichowski et al., 1993; Leikauf, 1992): acute exposure at 1.23 mg/m^3^ | | Robust; (↑ Hyperresponsive airways^b^)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictor allergen) (Note: unprovoked responses are not included) | Low | Human: [histamine challenge]: Hyperreactive airways with prolonged exposure (Górski and Krakowiak, 1991): ≥1 year exposure at ≤0.5 mg/m^3^, but N/C after acute exposure (Krakowiak et al., 1998): at 0.5 mg/m^3^; [allergen challenge]: hypersensitivity with acute exposure when exposure was restricted to mouth breathing in allergic asthmatics with a large allergen (mite) (Casset et al., 2006): acute exposure at 0.1 mg/m^3^; N/C after oronasal exposure in allergic asthmatics using a different allergen (pollen), including a methacholine (MCh) responsiveness test after allergen exposure (Ezratty et al., 2007): acute exposure at 0.5 mg/m^3^ | Suggestive evidence of increases with prolonged exposure, and possibly acute mouth-breathing exposure when challenged with specific allergens, but not acute exposure alone, to ≤0.5 mg/m^3^ in human adults; also, increased at ≥3 mg/m^3^ in short-term or acute studies across three species, particularly with prior sensitization | Robust; (↑ Hyperresponsive airways^b^)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictor allergen) (Note: unprovoked responses are not included) | Low | Animal: [MCh challenge]: Hyperresponsive airways (increased reactivity and sensitivity) with exposure in mice and rats (Wu et al., 2013; Qiao et al., 2009; Liu et al., 2011a): short-term exposure at ≥3 mg/m^3^, and in monkeys (Biagini et al., 1989): acute exposure at 3.1 mg/m^3^; in mice and rats, this response was amplified with OVA sensitization; TRP antagonists reduced the hyperresponsiveness in mice (Wu et al., 2013) | | Robust; (↑ Hyperresponsive airways^b^)
Sustained Inflammation | High or Medium | Human: Increased exhaled nitric oxide, a noninvasive and indirect marker of lower airway inflammation and oxidative stress, in healthy or asthmatic children (Franklin et al., 2000; Flamant-Hulin et al., 2010): unknown exposure duration (likely months to years; in classrooms or homes) at 0.04–0.06 mg/m^3^ | Immune cell counts are continually elevated in a subchronic mouse study with allergen stimulation at 2.46 mg/m^3^; increased biomarkers (indirect evidence) of lower airway inflammation are observed in children with prolonged exposure. | Moderate; (may require allergen sensitization)
Sustained Inflammation | High or Medium | Animal: Eosinophils and monocyte counts remain elevated with continued exposure for subchronic duration with allergen (OVA) sensitization (Fujimaki et al., 2004b): 12-week exposure at 2.46 mg/m^3^ | | Moderate; (may require allergen sensitization)
Sustained Inflammation | Low | Human: None | BAL cell counts and histologic evidence suggest that inflammation persists for several weeks with short-term exposure, and these effects are amplified by allergen | Moderate; (may require allergen sensitization)
Sustained Inflammation | Low | Animal: Immune cell counts were increased with short-term exposure in several studies at ≥0.5 mg/m^3^ (see Table 1-23; histological evidence of inflammation without epithelial damage was noted in short-term exposure studies, typically at higher concentrations, which were amplified by allergen (e.g., ≥3 mg/m^3^; (Wu et al., 2013; Kimura et al., 2010) | BAL cell counts and histologic evidence suggest that inflammation persists for several weeks with short-term exposure, and these effects are amplified by allergen | Moderate; (may require allergen sensitization)
↑ CD8+ T cells in LRT | High or Medium | Human: none | No evidence to evaluate | Slight; (at >7 mg/m^3^, but allergen stimulus unstudied) (note: mixed, indeterminate evidence for B cells, and CD4+ cells; Appendix A.5.6)
↑ CD8+ T cells in LRT | High or Medium | Animal: none | No evidence to evaluate | Slight; (at >7 mg/m^3^, but allergen stimulus unstudied) (note: mixed, indeterminate evidence for B cells, and CD4+ cells; Appendix A.5.6)
↑ CD8+ T cells in LRT | Low | Human: none | A study in rats and another in mice suggest that CD8+ T cells in the BAL might be increased after short-term exposure to high (>7 mg/m3) levels, although a second mouse study reported no changes | Slight; (at >7 mg/m^3^, but allergen stimulus unstudied) (note: mixed, indeterminate evidence for B cells, and CD4+ cells; Appendix A.5.6)
↑ CD8+ T cells in LRT | Low | Animal: Increased in short-term exposure studies in rats [at 7.4 mg/m^3^; (Sandikci et al., 2007b)] and mice [at 12.3 mg/m^3^; (Jung et al., 2007)]; no change with short-term exposure in a mouse study at ≥6.2-12.3 mg/m^3^ (Kim et al., 2013a) | A study in rats and another in mice suggest that CD8+ T cells in the BAL might be increased after short-term exposure to high (>7 mg/m3) levels, although a second mouse study reported no changes | Slight; (at >7 mg/m^3^, but allergen stimulus unstudied) (note: mixed, indeterminate evidence for B cells, and CD4+ cells; Appendix A.5.6)
↑ Th2-related (primarily) cytokines in LRT | High or Medium | Human: none | No evidence to evaluate | Slight; (↑ IL-4 at ≥0.5 mg/m^3^ and IL5 at >6 mg/m^3^); (note: mixed, indeterminate evidence for IL-10, IL-6, IL-13, and for Th1 cytokines; see Appendix A.5.6)
↑ Th2-related (primarily) cytokines in LRT | High or Medium | Animal: none | No evidence to evaluate | Slight; (↑ IL-4 at ≥0.5 mg/m^3^ and IL5 at >6 mg/m^3^); (note: mixed, indeterminate evidence for IL-10, IL-6, IL-13, and for Th1 cytokines; see Appendix A.5.6)
↑ Th2-related (primarily) cytokines in LRT | Low | Human: No change in IL-4 or IL-5 at 0.5 mg/m^3^ after acute exposure and pollen coexposure (Ezratty et al., 2007) | IL-4 was increased in shortterm studies of rats and mice at levels as low as 0.5 mg/m^3^, with amplified increases with antigen; IL-5 was increased in 2 of 3 studies in mice only testing higher (>6mg/m^3^) levels | Slight; (↑ IL-4 at ≥0.5 mg/m^3^ and IL5 at >6 mg/m^3^); (note: mixed, indeterminate evidence for IL-10, IL-6, IL-13, and for Th1 cytokines; see Appendix A.5.6)
↑ Th2-related (primarily) cytokines in LRT | Low | Animal: ↑ IL-4 in 4 studies in mice and one study in rats (all short-term exposure) testing exposures of 0.5-12.3 mg/m^3^ and observing larger increases with antigen (OVA) administration (Wu et al., 2013; Qiao et al., 2009; Lu et al., 2005; Liu et al., 2011a; Jung et al., 2007); ↑ IL-5 in 2 short-term exposure studies in mice at ≥6.2 mg/m^3^ (Sadakane et al., 2002; Jung et al., 2007); No change in IL-4 in a short-term exposure study in mice at >12.3 mg/m^3^ with co-administered house dust mite antigen (Sadakane et al., 2002)^c^ | | Slight; (↑ IL-4 at ≥0.5 mg/m^3^ and IL5 at >6 mg/m^3^); (note: mixed, indeterminate evidence for IL-10, IL-6, IL-13, and for Th1 cytokines; see Appendix A.5.6)
Modifications in the blood
[[See Table 3-22 for cellular and cytokine responses in the blood]]
Total IgE | High or Medium | Human: None | Slight (at ≥ 3 mg/m^3^); Based on no changes in a High or medium confidence subchronic mouse study at ≤2.46 mg/m^3^ and evidence of increased IgE in two short-term low confidence formalin studies in mice at ≥3 mg/m^3^, but no evidence for changes in low confidence studies in mice or humans at <2 mg/m^3^ | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgE | High or Medium | Animal: No evidence suggesting changes (Fujimaki et al., 2004b): subchronic exposure at ≤2.46 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgE | Low | Human: No evidence suggesting changes (Wantke et al., 1996b; Wantke et al., 2000; Palczynski et al., 1999; Ohmichi et al., 2006; Erdei et al., 2003): short-term exposure at ≤1.8 mg/m^3^ (duration in Erdei et al. unknown) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgE | Low | Animal: Evidence of increases in mice, which were increased further by OVA sensitization (Wu et al., 2013; Jung et al., 2007): short-term exposure at ≥3 mg/m^3^; evidence of no changes in mice by FA alone (Kim et al., 2013b; Gu et al., 2008), although FA exacerbated house dust mite-induced IgE (Kim et al., 2013b): short-term exposure at 0.12–1.2 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Formaldehyde (FA)-Specific IgE | High or Medium | Human: Elevated in one study of children (Wantke et al., 1996a): years of exposure (assumed) at ^~^0.06 compared to ^~^0.03 mg/m^3^ (note: elevations were unrelated to symptoms); N/C in adults (Kim et al., 1999): 4 years at 3.74 mg/m^3^ | Slight (in children); Based on increases in a High or medium confidence longterm study of children at <0.1 mg/m^3^; although, no changes were observed in a High or medium confidence long-term study of adults at 3.74 mg/m^3^ and there was no clear evidence of changes across multiple low confidence short-term and long-term studies in adults at ≤1.81 mg/m^3^ | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Formaldehyde (FA)-Specific IgE | High or Medium | Animal: None | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Formaldehyde (FA)-Specific IgE | Low | Human: No evidence of changes across multiple studies in adults (Zhou et al., 2005; Wantke et al., 1996b; Thrasher et al., 1987; Ohmichi et al., 2006; Górski and Krakowiak, 1991): short-term (weeks) or long-term (years) exposure at ^~^0.1–1.81 mg/m^3^; however, findings were unclear in two adult studies of long-term exposure in which a small proportion of subjects did have FA-IgE (Thrasher et al., 1990; Dykewicz et al., 1991), and one study noted slight increases with longer exposure (Wantke et al., 2000): 10 week, not 5 week, at 0.265 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Formaldehyde (FA)-Specific IgE | Low | Animal: No change in guinea pigs with acute challenge (Lee et al., 1984) at 2.5 or 4.9 mg/m^3^ after short-term exposure to 7.4 or 12.3 mg/m^3^ (note: no measures without formaldehyde and isotype was unspecified) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgE (does not include FAspecific Ig) | High or Medium | Human: None | Slight; Based on no changes in a High or medium confidence subchronic study with i.p. antigen sensitization and evidence in low confidence short-term studies in mice exposed to ≥1 mg/m^3^ that appears to be highly situational (e.g., dependent on duration and periodicity of formaldehyde exposure, and antigen type and administration route) | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgE (does not include FAspecific Ig) | High or Medium | Animal: N/C in OVA-IgE (Fujimaki et al., 2004b): 12 week exposure at 0.1–2.46 mg/m^3^ (OVA i.p.) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgE (does not include FAspecific Ig) | Low | Human: None | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgE (does not include FAspecific Ig) | Low | Animal: Increased OVA-specific IgE in mice in two short-term exposure studies (Tarkowski and Gorski, 1995; Gu et al., 2008): 10 d at 2 mg/m^3^ (but not 1 d/week for 7 week, or when OVA sensitization i.p.) and 5 week at 0.98 mg/m^3^ with i.p. OVA (but not ≤4 week), respectively; however, N/C in mice in three short-term (all 4-week) exposure studies: (Wu et al., 2013) at 3 mg/m^3^ with s.c. OVA sensitization, (Kim et al., 2013b) at 0.2–1.23 mg/m^3^ with dermal house dust mite (HDM) sensitization, and (Sadakane et al., 2002) at >12.3 mg/m^3^ with i.p. HDM sensitization^b^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgG | High or Medium | Human: Decreased in a single study of exposed workers (Aydın et al., 2013): 7 year exposure at 0.264 mg/m^3^ | Moderate; Based on decreased total IgG in a High or medium confidence long-term study in adult workers exposed to 0.264 mg/m^3^, and a High or medium confidence shortterm study in rats exposed to ≥6.15 mg/m^3^. IgG isoforms were affected in 2 of 3 low confidence shortterm mouse studies, but not a low confidence study of children at low levels | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgG | High or Medium | Animal: Decreased total IgG in rats (Sapmaz et al., 2015): short-term exposure at ≥6.15 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgG | Low | Human: N/C in children at ^~^0.007–0.07 mg/m^3^ (Erdei et al., 2003): unknown exposure duration (likely months-years) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Total IgG | Low | Animal: IgG1 (N/C in IgG2a) increased by FA alone, whereas FA exacerbated IgG2a increases (N/C in IgG1) in atopic-prone mice (Kim et al., 2013b): short-term exposure at 0.25, but not 1.2, mg/m^3^; increased IgG1 and IgG3, but decreased IgG2a and 2b, in C57 mice (Jung et al., 2007): short-term exposure at ≥6.15 mg/m^3^; N/C in IgG Balb/c mice (Gu et al., 2008): short-term exposure at <1 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
FA-Specific IgG | High or Medium | Human: Slight (i.e., <10%) increase in a single study of adults (Kim et al., 1999): years of exposure at 3.74 mg/m^3^ | Moderate; Based on slight increases in a High or medium confidence long-term study of adults at 3.74 mg/m^3^ and increases in low confidence studies of adults with longterm exposure at <1 mg/m^3^, but not with short-term exposure at higher levels; studies in children were not identified | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
FA-Specific IgG | High or Medium | Animal: None | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
FA-Specific IgG | Low | Human: Increased in two studies (Thrasher et al., 1987; Thrasher et al., 1990) and unclear in one study in which 5/55 subjects did have FA-IgG (Dykewicz et al., 1991): all three studies examined years of exposure at <0.1–<1.0 mg/m^3^; N/C in one study (Wantke et al., 2000): short-term exposure at 0.265 mg/m^3^ | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
FA-Specific IgG | Low | Animal: No change in guinea pigs with acute challenge (Lee et al., 1984) at 2.5 or 4.9 mg/m^3^ after short-term exposure to 7.4 or 12.3 mg/m^3^ (note: the study did not present measures without formaldehyde exposure, and isotype was unspecified) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgG (does not include FAspecific Ig) | High or Medium | Human: None | Moderate (with inhaled antigen); Based on increased OVAIgG1 in a High or medium confidence short-term study in guinea pigs at 0.31 mg/m^3^ with inhaled allergen, but not a longer High or medium confidence mouse study at similar levels using injected allergen. Similarly, a longterm low confidence study observed increased IgG sensitization to airway antigens in children, whereas several low confidence studies in mice and rats suggest that IgG sensitization does not occur when antigen is injected. | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgG (does not include FAspecific Ig) | High or Medium | Animal: Increased OVA-specific IgG1 in guinea pigs (Riedel et al., 1996): 5 d at 0.31 mg/m^3^ with inhaled OVA; questionable decrease (i.e., effects were observed at 0.49, but not 2.46, mg/m^3^) in OVA-IgG1 and OVA-IgG3 in mice (Fujimaki et al., 2004b): 12 weeks exposure with i.p. OVA sensitization (N/C in OVA-IgG2) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgG (does not include FAspecific Ig) | Low | Human: Increased IgG against 2 bacterial pathogens in 3^rd^ grade children with respiratory complaints (Erdei et al., 2003): <0.1 mg/m^3^, unknown exposure duration (likely years, home measures) | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
Antigen-Specific IgG (does not include FAspecific Ig) | Low | Animal: N/C in OVA-IgG or Der f-IgG1 in mice (Wu et al., 2013; Sadakane et al., 2002; Gu et al., 2008): up to 5 week exposures at 0.123–3 mg/m^3^ or >12.3 mg/m^3 b^; N/C in IgG specific to vaccine antigens in rats (Holmstrom et al., 1989a): 22 months exposure at 15.5 mg/m^3^. In all cases, s.c. or i.p. exposure was used for sensitization | | Moderate for IgG; Slight for IgE (only with specific exposure scenarios); Indeterminate for IgM or IgA (i.e., very little evidence; data not shown: see Appendix A.5.6)
↑ Circulating Stress Hormones | High or Medium | Human: None | Increased at 3 mg/m^3^ formaldehyde in a study in rats with short-term, but not acute, exposure | Slight
↑ Circulating Stress Hormones | High or Medium | Animal: Increased corticosterone in rats with short-term, but not acute, exposure (Sorg et al., 2001a): at ^~^3 mg/m^3^ | Increased at 3 mg/m^3^ formaldehyde in a study in rats with short-term, but not acute, exposure | Slight
↑ Circulating Stress Hormones | Low | Human: None | No evidence to evaluate | Slight
↑ Circulating Stress Hormones | Low | Animal: None | No evidence to evaluate | Slight
Modifications in other non-Respiratory Tissues
↑ Oxidative stress in nonrespiratory tissues | High or Medium | Human: Increased marker of lipid peroxidation in adult serum lymphocytes (Bono et al., 2010): likely months-to-years exposure (assumed) at ≥0.066 mg/m^3^; Increased F2-Isoprostanes (suggested as the best in vivo biomarker of lipid peroxidation) in urine (Romanazzi et al., 2013): 0.21 mg/m^3^ chronic occupational exposure (indirect for effects in blood), although smoking and formaldehyde were not additive, both were independently associated with ROS―Note: serum and urine IsoP measures are often correlated [e.g., (Rodrigo et al., 2007)], suggesting that urine levels may reflect similar serum changes | Two studies in adults indicate elevated oxidative stress markers at ≥0.066–0.21 mg/m^3^ with long-term exposure. Given the uncertainty regarding use of urine to reflect associations in blood, one study contributes as indirect evidence | Moderate
↑ Oxidative stress in nonrespiratory tissues | High or Medium | Animal: None | | Moderate
↑ Oxidative stress in nonrespiratory tissues | Low | Human: Increased oxidative stress biomarkers (F2-Isoprostanes; malondialdehyde) in urine (Bellisario et al., 2016): work-shift exposure at ^~^0.034 mg/m^3^ (indirect for effects in blood; responses likely reflect short-term exposure) | Several studies in three species suggest increases in markers of oxidative stress with acute or short-term exposure, even at formaldehyde levels ≤1 mg/m^3^; it is not clear whether and to what extent this persists with long-term exposure | Moderate
↑ Oxidative stress in nonrespiratory tissues | Low | Animal: Increased oxidative stress markers in mice (Ye et al., 2013b; Matsuoka et al., 2010): acute or short-term exposures at as low as 0.12 mg/m^3^; increased oxidative stress markers and protein indicators in rats (Im et al., 2006; Aydin et al., 2014): short-term exposure at 6.48–12.3 mg/m^3^, although one study with a longer exposure (10 week) observed a decrease in MDA in rats (Katsnelson et al., 2013): at 12.8 mg/m^3^; other indicators in rodents included decreased GSH (Ye et al., 2013b; Katsnelson et al., 2013) and increased NO and SOD (Matsuoka et al., 2010): short-term exposure at ≥1 mg/m^3^ | | Moderate
Cell counts in immune tissues (not including bone marrow) | High or Medium | Human: None | Suppression of CD8+ T cells in immune tissues (e.g., spleen) is indicated in one 8-week mouse study, with indirect support from a second short-term mouse study, at around 2 mg/m^3^; effects on CD4^+^/CD8^+^ ratio were mixed across 2 subchronic mouse studies | Moderate (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | High or Medium | Animal: Decreased CD8+ T cells and increased CD4^+^/CD8^+^ ratio in both thymus (immature immune cells) and spleen (mature immune cells) in male mice (Ma et al., 2020): Eight weeks of exposure at 2 mg/m^3^; No change in splenic CD4^+^/CD8^+^ ratio in female mice (Fujimaki et al., 2004b): 12 week at up to 2.46 mg/m^3^; Increased splenic regulatory T cells (subset of CD4+) and indirect markers for suppression of effector T cell (CD8+) activity in female mice (Park et al., 2020): short-term exposure at ≥1.38 mg/m^3^ | | Moderate (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | Low | Human: None | Multiple [underlined: short-term] mouse studies suggest that overall splenic cell T and B cells are unchanged; however, 2 studies suggest that NK cells may be affected (1 study showed NK cells were stimulated at low formaldehyde levels, and another that high levels are inhibitory/toxic) | Moderate (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | Low | Animal: N/C in tissue weight, total cellularity or T or B cell counts in mice (Kim et al., 2013a; Gu et al., 2008; Dean et al., 1984); altered NK cell number and function was noted in mice, with one study showing decreases (Kim et al., 2013a): 2–3 week at 12.3 mg/m^3^, and another showing increases (Gu et al., 2008): 5 week at up to 0.12 mg/m^3^, and a third showing N/C in lymphocyte proliferation, functional parameters, IgM production, or NK cytotoxicity (Dean et al., 1984): 3 week at 18.5 mg/m^3^ | | Moderate (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (↑ at low level; ↓ at high level); Indeterminate for other cell counts
Systemic indicators of altered immune function | High or Medium | Human: None | No evidence to evaluate | Indeterminate
Systemic indicators of altered immune function | High or Medium | Animal: None | No evidence to evaluate | Indeterminate
Systemic indicators of altered immune function | Low | Human: Increased autoantibodies in adults (Thrasher et al., 1990): long-term exposure at 0.06–0.95 mg/m^3^ | 1 study in adults suggests that autoantibodies are elevated with low-level, long-term exposure; somewhat in contrast, one mouse study suggests short-term high-level exposure improves host response to bacteria | Indeterminate
Systemic indicators of altered immune function | Low | Animal: Improved cell-mediated immune response to bacteria challenge, but N/C against tumor challenge or delayed-type hypersensitivity response in mice (Dean et al., 1984): 3 week exposure at 18.5 mg/m^3^ (Note: N/C in vitro measures of immune cell function in the same study) | | Indeterminate

a Several studies examining the lineage and maturity of immune and non-immune cells in the bone marrow and other systemic tissues (e.g., blood; spleen) are not discussed in this section. Although it is possible that differences in the maturation phenotype of cells could indirectly contribute to the immune changes of interest to this section, such alterations would be expected to cause functional or other detectable changes in more apical mechanistic events relevant to immune responses in the respiratory system. Thus, this discussion focuses on those mechanistic events considered more directly relevant to these POE outcomes. Please see Section 3.3.3 for a discussion of these cell lineage and maturation markers in the context of lymphohematopoietic cancer MOA.

b As the challenge stimuli used in the formaldehyde studies included allergens as well as nonimmunological stimuli, and because most experiments did not attempt to delineate the specifics of the functional changes, “airway hyperresponsiveness” or “hyperresponsive airways” encompasses any of a range of possible airway features: hyperreactivity (exaggerated response), hypersensitivity (lower dose to elicit response), altered ventilatory parameters (e.g., maximal response, resistance), recovery (longevity of response), or others.

c Reported as 0.5% formaldehyde solution; concentration assumed to be >12.3 mg/m^3^ (Sadakane et al., 2002).

Table 3-22 Summary of changes in cell counts and soluble immunological factors in the blood following formaldehyde exposure

Endpoint | | | No changes observed | | | Significant^a^ increases (↑) or decreases (↓) | | | Conclusion; (notes)
Endpoint | | | (above dashed line= human studies; below dashed line= animal studies; high or medium confidence = *and bold) | | | (above dashed line= human studies; below dashed line= animal studies; high or medium confidence = *and bold) | | | Conclusion; (notes)
Endpoint | | | mg/m^3^ | Length^b^ | References (details) | mg/m^3^ | Length^b^ | References (details) | Conclusion; (notes)
White blood cells (WBCs) | Total WBCs | | 0.87; 0.25; 0.018 | Years; Years; Years^c^ | (Lyapina et al., 2004)*; (Aydın et al., 2013)*; (Erdei et al., 2003); (asthmatic children) | ↓ 1.6; ↓ N/A^e^; (≤1); ↓≤0.29 | Years (same cohort); Year vs. Mo Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)*^d^; (Bassig et al., 2016)*; (Thrasher et al., 1990); (Kuo et al., 1997) | Moderate ↓ in WBCs^g^
White blood cells (WBCs) | Total WBCs | | ≥9.23 | 8 week | (Morgan et al., 2017); (mice)* | ≥2.46^f^; (indirect); ↓ 0.5–3 | Short; Short | (Rager et al., 2014)* (rats); (Zhang et al., 2013b) (mice) | Moderate ↓ in WBCs^g^
White blood cells (WBCs) | Granulocytes | All | | | | ↓ 1.6 | Years (same cohort) | (Hosgood et al., 2013)*;; (Zhang et al., 2010)*^d^; (Bassig et al., 2016)* | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | All | 18.5 | Short | (Dean et al., 1984) (mice)^h^ | | | | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Neutrophils | 0.25; ≤0.29; 0.018 | Years; Years; Years^c^ | (Aydın et al., 2013)*; (Kuo et al., 1997); (Erdei et al., 2003); (asthmatic children) | ↓ 0.87 | Years | (Lyapina et al., 2004)*; (i.e., function, in workers with URT dysfunction) | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Neutrophils | ≥9.23; 0.5–3 | 8 week; Short | (Morgan et al., 2017); (mice) (mice); (Zhang et al., 2013b) (mice) | ↓ 13 | Short | (Katsnelson et al., 2013); (rats) | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Eosinophils | ≤0.29; 0.018 | Years; Years^c^ | (Kuo et al., 1997); (Erdei et al., 2003); (asthmatic children) | | | | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Eosinophils | ≥9.23 | 8 week | (Morgan et al., 2017); (mice) (mice) | | | | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Basophils | ≤0.29 | Years | (Kuo et al., 1997) | | | | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Granulocytes | Basophils | No animal studies identified | | | | | | Slight ↓ in granulocytes (appears to reflect potential changes in neutrophils at higher concentrations with short-term or longer exposure)
White blood cells (WBCs) | Lymphocytes | All | 0.2 & 0.8; N/A^e^ (≤1); 0.51; ≤0.29; 0.018 | Months; Year vs. Mo Weeks; Years; Years^c^ | (Jia et al., 2014)*; (Thrasher et al., 1990) (Ying et al., 1999); (Kuo et al., 1997); (Erdei et al., 2003); (asthmatic children) | ↓ 1.6; ↑ 0.25 | Years; (same cohort); Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Bassig et al., 2016)*; (Aydın et al., 2013)* | Indeterminate (multiple changes noted, but pattern is indiscernible)
White blood cells (WBCs) | Lymphocytes | All | 18.5; ≥9.23 | Short; 8 week | (Dean et al., 1984) (mice)^h^; (Morgan et al., 2017)*; (mice) | ↑ 13; ↓ 0.5–3 | Short; Short | (Katsnelson et al., 2013); (rats); (Zhang et al., 2013b) (mice) | Indeterminate (multiple changes noted, but pattern is indiscernible)
White blood cells (WBCs) | Lymphocytes | B Cells | 1.6; 0.25; 0.09–0.7 | Years; (same cohort); Years; Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)*; (Bassig et al., 2016)*; (Aydın et al., 2013)*; (Thrasher et al., 1987) | ↑ 0.99; ↑ 0.2 & 0.8; ↑ N/A^e^; (≤1); ↑ 0.51; ↓ 0.47; ↓ 0.36 | Months; Months; Year vs. Mo Weeks; Years; Years | (Ye et al., 2005)* (peak levels up to 1.69 mg/m^3^); (Jia et al., 2014)*; (Thrasher et al., 1990) (Ying et al., 1999); (Costa et al., 2019)* (peak levels to 3.94 mg/m^3^); (Costa et al., 2013)* (peak levels to 0.69 mg/m^3^) | Moderate for altered number of B cells (direction of change may differ by exposure levels or duration)
White blood cells (WBCs) | Lymphocytes | B Cells | No animal studies identified | | | | | | Moderate for altered number of B cells (direction of change may differ by exposure levels or duration)
White blood cells (WBCs) | Lymphocytes | T Cells (Total) | 0.2–0.8; N/A^e^ (≤1) | Months; Year vs. Mo | (Jia et al., 2014)*; (Thrasher et al., 1990) | ↓ 1.6; ↓ 0.99; ↑ 0.36; ↑ 0.25; ↓ 0.9; ↓ 0.51; ↓ ≥0.09 | Years; (same cohort); Months; Years; Years; Years; Weeks; Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Bassig et al., 2016)*; (Ye et al., 2005)*; (peak levels to 1.69 mg/m^3^); (Costa et al., 2013)* (peak levels to 0.69 mg/m^3^); (Aydın et al., 2013)*; (Jakab et al., 2010); (Ying et al., 1999); (Thrasher et al., 1987); (levels up to 0.68 mg/m^3^) | Slight for altered total T cells; (mixed results suggest dosedependence, with ↓ at higher levels; possible ↑ at low levels, with longer duration)
White blood cells (WBCs) | Lymphocytes | T Cells (Total) | | | | ↑ 7.4 | Short | (Sandikci et al., 2007a, b); (rats) | Slight for altered total T cells; (mixed results suggest dosedependence, with ↓ at higher levels; possible ↑ at low levels, with longer duration)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | 1.6 | Years; (same cohort) | (Hosgood et al., 2013)*; (note: ↓ T_reg_ cells); (Zhang et al., 2010)*; (Bassig et al., 2016)* | ↑ 0.36; ↓ 0.51 | Years; Weeks | (Costa et al., 2013) * (peak levels to 0.69 mg/m^3^); (Ying et al., 1999) | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | 0.99 | Months | ( Ye et al., 2005 )* (peak levels up to 1.69 mg/m^3^) | ↑ 0.36; ↓ 0.51 | Years; Weeks | (Costa et al., 2013) * (peak levels to 0.69 mg/m^3^); (Ying et al., 1999) | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | 0.47 | Years | ( Costa et al., 2019 )* (peak levels to 3.94 mg/m^3^) | ↑ 0.36; ↓ 0.51 | Years; Weeks | (Costa et al., 2013) * (peak levels to 0.69 mg/m^3^); (Ying et al., 1999) | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | 0.25 | Years | ( Aydın et al., 2013 )* | ↑ 0.36; ↓ 0.51 | Years; Weeks | (Costa et al., 2013) * (peak levels to 0.69 mg/m^3^); (Ying et al., 1999) | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | 0.2–0.8 | Months | ( Jia et al., 2014 )* | ↑ 0.36; ↓ 0.51 | Years; Weeks | (Costa et al., 2013) * (peak levels to 0.69 mg/m^3^); (Ying et al., 1999) | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells; (CD4^+^) | No animal studies identified | | | | | | Indeterminate (mostly N/C, but variable and, considering also studies of spleen (above), suggests effects might exist for certain subsets of CD4 cells)
White blood cells (WBCs) | Lymphocytes | T Cells (CD8^+^) | 0.36; 0.25; 0.2–0.8 | Years; Years; Months | (Costa et al., 2013)* (peak levels to 0.69 mg/m^3^); (Aydın et al., 2013)*; (Jia et al., 2014)* | ↓ 1.6; ↓ 0.99; ↓ 0.51; ↑ 0.47 | Years (same cohort); Months; Weeks; Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Bassig et al., 2016)* (particularly memory cells); (Ye et al., 2005)* (peak levels to 1.69 mg/m^3^); (Ying et al., 1999); (Costa et al., 2019)* (peak levels to 3.94 mg/m^3^) | Moderate; ↓ CD8 and ↑ CD4/CD8 ratio (likely dosedependence, as consistent observations are at higher levels)
White blood cells (WBCs) | Lymphocytes | T Cells (CD8^+^) | N/C CD4/CD8 ratio in these 3 studies (or in (Thrasher et al., 1990) comparing durations) | | | ↑ CD4/CD8 ratio in all but one of these studies | | | Moderate; ↓ CD8 and ↑ CD4/CD8 ratio (likely dosedependence, as consistent observations are at higher levels)
White blood cells (WBCs) | Lymphocytes | T Cells (CD8^+^) | No animal studies identified | | | | | | Moderate; ↓ CD8 and ↑ CD4/CD8 ratio (likely dosedependence, as consistent observations are at higher levels)
White blood cells (WBCs) | Lymphocytes | NK Cells | | | | ↓ 1.6; ↓ 0.36; ↑ 0.25; ↑ 0.2; N/C at 0.8 | Years; (same cohort); Years; Years; Months | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^;; (Bassig et al., 2016)*; (Costa et al., 2013)* (peak levels to 0.69 mg/m^3^); (Aydın et al., 2013)*; (Jia et al., 2014)* | Slight for altered number of NK cells (mixed results suggest dosedependence like total T cells)
White blood cells (WBCs) | Lymphocytes | NK Cells | No animal studies identified | | | | | | Slight for altered number of NK cells (mixed results suggest dosedependence like total T cells)
White blood cells (WBCs) | Monocytes | | 1.6; 0.25 | Years; (same cohort); Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Bassig et al., 2016)*; (Aydın et al., 2013)* | ↑ 0.018 | Years^c^ | (Erdei et al., 2003); (asthmatic children) | Indeterminate; (data suggest N/C, at least in human adults)
White blood cells (WBCs) | Monocytes | | ≥9.23 | 8 week | (Morgan et al., 2017); (mice) | ↓ 18.5; ↓ 0.5, not; 3 | Short; Short | (Dean et al., 1984) (mice); (Zhang et al., 2013b) (mice) | Indeterminate; (data suggest N/C, at least in human adults)
Red Blood Cells | | | 0.25; ≤0.29; 0.018 | Years; Years; Years^c^ | (Aydın et al., 2013)*; (Kuo et al., 1997); (Erdei et al., 2003); (asthmatic children) | ↓ 1.6; ↓ 0.87 | Years; Years | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Lyapina et al., 2004)* (association with duration) | Moderate ↓in RBCs^i^; (suggests dose- and duration-dependence)
Red Blood Cells | | | ≥9.23 | 8 week | (Morgan et al., 2017); (mice) | ↓ 0.5–3 | Short | (Zhang et al., 2013b) (mice) | Moderate ↓in RBCs^i^; (suggests dose- and duration-dependence)
Platelets | | | 0.87; ≤0.29; 0.018 | Years; Years; Years^c^ | (Aydın et al., 2013)*; (Kuo et al., 1997); (Erdei et al., 2003); (asthmatic children) | ↓ 1.6 | Years; (same cohort) | (Hosgood et al., 2013)*;; (Zhang et al., 2010)* ^d^; (Bassig et al., 2016)* | Slight ↓ in platelets^j^; (possible dose-dependence as noted above)
Platelets | | | ≥9.23 | 8 week | (Morgan et al., 2017); (mice) | ↑ 0.5–3 | Short | (Zhang et al., 2013b) (mice) | Slight ↓ in platelets^j^; (possible dose-dependence as noted above)
Secreted factors and immune | Primarily Th1-related | TNF-α | 1.8; 0.2–0.8 | Years; Months | (Seow et al., 2015)* (peak levels to 6.9 mg/m^3^); (Jia et al., 2014)* | ↑ 0.25 | Years | ( Aydın et al., 2013 )* | Slight ↑; TNF-α and C3
Secreted factors and immune | Primarily Th1-related | TNF-α | No animal studies identified | | | | | | Slight ↑; TNF-α and C3
Secreted factors and immune | Primarily Th1-related | Complement | 0.25 | Years | (Aydın et al., 2013)*; (i.e., C3, C4) | | | | Slight ↑; TNF-α and C3
Secreted factors and immune | Primarily Th1-related | Complement | | | | ↑ 6.15 | Short | ( Sapmaz et al., 2015 )* (rats; i.e., C3) | Slight ↑; TNF-α and C3
Secreted factors and immune | Primarily Th1-related | IFN-γ | | | | ↓ 0.8 | Months | ( Jia et al., 2014 )* | Moderate ↓; IFN-γ
Secreted factors and immune | Primarily Th1-related | IFN-γ | | | | ↓ 6.2–12.3 | Short | (Im et al., 2006) (rats) | Moderate ↓; IFN-γ
Secreted factors and immune | Primarily Th2-related | IL-4 | | | | ↑ 0.8 | Months | ( Jia et al., 2014 )* | Moderate ↑; IL-4
Secreted factors and immune | Primarily Th2-related | IL-4 | | | | ↑ 6.2–12.3 | Short | (Im et al., 2006) (rats) | Moderate ↑; IL-4
Secreted factors and immune | Primarily Th2-related | IL-10 | | | | ↓ 1.8; ↑ 0.2–0.8 | Years; Months | (Seow et al., 2015)* ^d^; (i.e., using less strict 20% FDR); (Jia et al., 2014)* | Slight; IL-10; (suggests dosedependence like total T cells)
Secreted factors and immune | Primarily Th2-related | IL-10 | No animal studies identified | | | | | | Slight; IL-10; (suggests dosedependence like total T cells)
Secreted factors and immune | Primarily Th2-related | IL-6 | No human studies identified | | | | | | Indeterminate; IL-6
Secreted factors and immune | Primarily Th2-related | IL-6 | 0.12 | Acute | (Matsuoka et al., 2010); (mice) | | | | Indeterminate; IL-6
Secreted factors and immune | Chemoattractants | CXCL1 1 and CCL17 | | | | ↓ 1.8 | Years | (Seow et al., 2015)*; (i.e., using stringent 10% FDR) | Slight ↓; (chemo-attractants for neutrophils: IL-8, and lymphocytes: Cxcl11, Ccl17)
Secreted factors and immune | Chemoattractants | CXCL1 1 and CCL17 | No animal studies identified | | | | | | Slight ↓; (chemo-attractants for neutrophils: IL-8, and lymphocytes: Cxcl11, Ccl17)
Secreted factors and immune | Chemoattractants | IL-8 | | | | ↓ 0.2–0.8 | Months | ( Jia et al., 2014 )* | Slight ↓; (chemo-attractants for neutrophils: IL-8, and lymphocytes: Cxcl11, Ccl17)
Secreted factors and immune | Chemoattractants | IL-8 | No animal studies identified | | | | | | Slight ↓; (chemo-attractants for neutrophils: IL-8, and lymphocytes: Cxcl11, Ccl17)
Secreted factors and immune | Other | Ta1 and IL-2R | | | | ↑ N/A^e^; (≤1) | Year vs. Mo | (Thrasher et al., 1990); (antigen reactivity markers) | Indeterminate; (data suggest N/C in B cell activation markers)
Secreted factors and immune | Other | Ta1 and IL-2R | No animal studies identified | | | | | | Indeterminate; (data suggest N/C in B cell activation markers)
Secreted factors and immune | Other | CD27 and CD30 | 1.6 | Years | (Bassig et al., 2016)*; (B cell activation markers) | | | | Indeterminate; (data suggest N/C in B cell activation markers)
Secreted factors and immune | Other | CD27 and CD30 | No animal studies identified | | | | | | Indeterminate; (data suggest N/C in B cell activation markers)

Abbreviations and definitions: Der f = Dermatophagoides farina (house dust mite) and OVA = ovalbumin (major protein of chicken egg whites): both immunogenic materials used to stimulate an allergy-like response; FDR = false discovery rate; N/C = no change; T_reg_ = T regulatory cells, a subset of helper T cells; short = short-term.

Notes: Formaldehyde concentrations typically reflect average or median levels in human studies (e.g., when effects were not observed); Gray shading = no data meeting the inclusion criteria were available (see Appendix B.2.6 and B.3.6); one study observing increased substance P and related changes in the serum (Fujimaki et al., 2004b) was previously presented in the context of changes in the respiratory system (see Section 3.2.2).

a Primarily, this reflects reporting of a statistically significant change; in rare instances where a p-value was not given, changes are indicated if the authors discussed the change as a significant effect.

b Human study exposure durations are indicated as “years,” “months,” “weeks,” “acute,” or “Year vs. Mo” (see footnote d) and defined based on the anticipated exposure duration for the majority of the exposed population(s); these durations are interpreted to approximate animal study exposure durations of chronic (>1 year), subchronic (several months), short term (“Short” in table; <30 days), and acute (1 day or less).

c Erdei et al. (2003) studied 9- to 11-year-old students symptomatic with respiratory issues, so duration of exposure was presumed to be years in schools (average exposure concentration is indicated).

d The differences in lymphocyte subset levels between exposed and unexposed workers reported by Zhang et al. (2010) were challenged by Mundt et al. (2017) in a reanalysis who did not find evidence of an exposure-response trend within the exposed group, although the difference between unexposed and exposed subjects was reconfirmed. The critique by Mundt was responded to in a letter to the editor by the study investigators who explained that the study was not designed to provide a range of exposures wide enough to evaluate exposure-response relationships given the expected effect size and sample size in the study (Rothman et al., 2017).

e The exposure level is, in general, considered not applicable (N/A), as the comparison presented by Thrasher et al. (1990) reflected differences in exposure duration (i.e., years of exposure [Year], as compared to weeks or months [Mo] of exposure), but there appeared to be minimal differences in concentration from the controls.

f The studies by (Rager et al., 2013; Rager et al., 2014) were molecular studies (e.g., miRNA) interpreted as high or medium confidence that provide some indirect evidence of inflammatory changes.

g This finding (decreased total WBCs) is supported by three studies in humans based on an evaluation by NRC (2014b): [(Tong et al., 2007; Tang and Zhang, 2003; Cheng et al., 2004)], but these studies were not evaluated in this analysis (i.e., they were not indexed in any of the searched databases); additionally, this finding is supported by a study in mice (Yu et al., 2014) and a study in rats (Brondeau et al., 1990), which are not included above as they only tested excessive formaldehyde levels (i.e., ≥20 mg/m^3^).

h The authors indicated no changes in “WBC differentials” other than decreased monocytes, but further details NR (Dean et al., 1984). This test was assumed to include basic granulocyte and lymphocyte counts.

i This finding (decreased erythrocytes) is supported by one study in humans based on an evaluation by the NRC (2014b): [(Yang, 2007)], but this study was not evaluated in this analysis.

j This finding (decreased platelets) is supported by two studies in humans based on an evaluation by NRC (2014b): (Yang, 2007; Tong et al., 2007), but these studies were not evaluated in this analysis. The finding is also supported by a mouse study testing excessive formaldehyde levels (Yu et al., 2014).

##### Summary of Inferences Regarding Mode of Action

Understanding of the partial MOA likely to underly the development of allergic conditions and effects on the prevalence of current asthma following formaldehyde inhalation is primarily based on experimental studies in animals. This strong mechanistic evidence alone is considered to support an animal evidence synthesis judgment of slight (see above).

#### Evidence Integration Summary

The general population studies in children and adults provide moderate evidence of an association between formaldehyde exposure and prevalence of rhinitis or rhinoconjunctivitis, with a relative risk of approximately 1.2 for formaldehyde exposures of around 0.04 mg/m^3^ and above. Although the effect size is small, these are relatively common conditions. The observation of an increase in the magnitude of the association with increasing severity of rhinitis provides coherence and greater certainty in the evidence (Yon et al., 2019). A stronger association (2-fold risk) was seen in the only study of eczema and a 3-fold risks of experiencing allergy-like symptoms involving the eyes, nose or skin within the past week was observed for students exposed to formaldehyde concentrations in classrooms >0.035 mg/m^3^ (median 0.045 mg/m^3^) compared to <0.035 mg/m^3^ (OR 3.23, 95% CI 1.31, 8.00).

The available general population and occupational studies also provide a moderate level of evidence of an association between formaldehyde exposure and prevalence of current asthma, as determined by symptoms or medication use in the past 12 months for asthma in studies with exposures above 0.05 mg/m^3^. The pattern of results across studies in children indicates no association at exposures < 0.05 mg/m^3^, and a moderate association (RRs around 2.0) in residential or school-exposures above 0.05 (the maximum levels seen in these studies was generally around 0.08-0.10 mg/m^3^). Stronger associations were seen in studies examining prevalence of current asthma in relation to higher levels of formaldehyde exposure in occupational settings (RR 2-5 for exposures above 0.10 mg/m^3^). The two studies examining asthma control or severity among children with asthma suggest associations may be seen at lower exposures (e.g., 0.04 mg/m^3^) in this potentially susceptible population.

Sensitivity may also be increased by other attributes as well disease severity. Although associations with either eczema, prevalence of asthma, or asthma control were either increased or decreased by a positive atopy status in studies of adults or children, studies in allergen-sensitized animals suggest that atopy may increase sensitivity to formaldehyde-related asthma endpoints. In addition, associations with IgE levels or prevalence of asthma symptoms were stronger among groups exposed to environmental tobacco smoke, although inconsistencies by lifestage were reported. Relatively strong associations were seen in studies examining prevalence of current asthma in relation to higher levels of formaldehyde exposure in occupational settings (exposures above 0.10 mg/m^3^). Mechanistic studies in animals indicate that formaldehyde exposure can induce bronchoconstriction with and without allergen sensitization. This heightened bronchoconstriction response may be due to a combination of increased tachykinins, increased T_H_2 cytokines and antibodies, and eosinophil recruitment and activation in the lung. Mechanistic studies of respiratory tissues and the blood provide consistent evidence that formaldehyde exposure can stimulate a number of immunological and neurological processes that may drive asthmatic responses; however, a molecular understanding of how formaldehyde exposure favors asthmatic T_H_2 responses has not been experimentally established. Separately, the possibility that formaldehyde exposure might increase the risk or severity of respiratory infections, particularly in young children, has not been well studied.

Overall, based primarily on a moderate level of human evidence supporting an association from the available epidemiology studies, with corresponding slight evidence for an effect in animals based on mechanistic studies in animals supporting biological plausibility, the evidence indicates that inhalation of formaldehyde likely causes an increased risk of prevalent allergic conditions and prevalent asthma symptoms, as well as decreased control of asthma symptoms, given sufficient exposure conditions (see Table 3-23). The primary basis for this conclusion involves studies of occupational settings (>0.1 mg/m^3^) and population studies where formaldehyde concentrations measured in schools and homes were > 0.05 mg/m^3^, although lower exposures (above 0.03 mg/m^3^ may be relevant with respect to control of asthma symptoms.

Table 3-23

Evidence integration summary for effects of formaldehyde inhalation on allergic conditions

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Allergic Conditions
Human | Consistency and Study Confidence | - Elevated risks for at least one allergic symptom were consistently observed in the seven high and medium confidence studies among adults and children in residential and school settings with exposures around 0.04 mg/m^3^ formaldehyde and above.; - The minority of studies (two) that did not observe an association did not reduce certainty, as they were conducted in lower exposure settings (0.004-< 0.025 mg/m3) | | Moderate (for allergic conditions); Consistent and dosedependent, but small, elevations in risk for allergy-related conditions in residential and school settings around 0.04 mg/m^3^ and above across varied study designs and populations. | The evidence indicates that inhalation of formaldehyde likely increases the prevalence of allergic conditions in humans, given sufficient exposure conditions^a^; This judgment is primarily based on studies of residential and school settings where mean formaldehyde concentrations were around 0.05 mg/m^3^ and above.; Potential Susceptibilities: Variation in sensitivity is anticipated depending on respiratory health, physiologic changes during pregnancy, age, and exposure to tobacco smoke.
Human | Strength and Precision | | - Effect sizes for rhinitis and rhinoconjunctivitis were small (RR around 1.2); however, because these are relatively common conditions, even small risks can be meaningful on a population level
Human | Dose-Response | - Increasing risk was seen across levels of rhinitis severity and in the studies examining more than two exposure groups
Human | Coherence | - Findings included increases in the prevalence of several potentially related conditions, including rhinitis, rhinoconjunctivitis, and eczema
Human | Biological Plausibility | Studies in humans do not provide robust or moderate evidence for mechanistic events that clearly support the development of allergic conditions, although observed effects in the blood, such as cytokine, cell, and antibody changes, might contribute.
Animal | Experimental animal models are generally considered to be unable to reproduce the overt manifestations of allergic conditions and are not interpreted to provide direct support. | | | Slight (for immunemediated respiratory effects); The available animal studies most relevant to evaluating potential effects on allergic conditions and other mechanistic information were interpreted to provide slight animal evidence for an effect.
Animal | Biological Plausibility | - Understanding of the partial MOA likely to underly the development of allergic conditions following formaldehyde inhalation is primarily based on experimental studies in animals. This strong mechanistic evidence alone is considered to support an animal evidence synthesis judgment stronger than indeterminate.
Other inferences | - Relevance to humans: The primary effect of interest was observed in humans (moderate evidence).; - MOA: Not established, but several incomplete MOAs involving airway inflammatory changes are considered likely to be involved, contributing to augmented or hyperactive airway responses. Specifically, robust evidence for mechanistic events exists in relation to formaldehyde-induced augmentation of responses to allergens and airway bronchoconstrictor effects in animal models. Although several events typically associated with asthma were not corroborated (i.e., slight or indeterminate evidence exists for these events), moderate evidence for mechanistic events exists for stimulation by formaldehyde of important immunological and neurological processes. These include airway eosinophil increases and other inflammatory changes in the airways and systemic circulation that can be reasonably associated with effects on airway hyperreactivity or other responses relevant to the development of allergic conditions and, potentially, asthma. The most relevant mechanistic findings in animals involve neurological and immunological constituents present in both human and rodent airways, so these findings are considered relevant to humans.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

Table 3-24

Evidence integration summary for effects of formaldehyde inhalation on asthma

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Prevalence of Current Asthma
Human | Consistency and Study Confidence | - Elevated risks were consistently observed in nine medium confidence studies of prevalence of current asthma in residences or schools at exposures above 0.05 mg/m^3^ and in three medium confidence studies in occupational settings with exposures from 0.100 to >0.500 mg/m^3^; greater susceptibility was observed among children.; - The minority of studies (five studies in residences or schools) that did not observe an association with formaldehyde exposure did not reduce certainty, as they were conducted in lower exposure settings (< 0.05 mg/m^3^). | | Moderate (for asthma) Consistently elevated risks for increased prevalence of asthma or decreased control of asthma symptoms around 0.050 mg/m^3^ and above across medium confidence studies in residential and school settings, with higher risks at higher exposures in occupational settings supporting dosedependence. | The evidence indicates that inhalation of formaldehyde likely increases the prevalence of asthma symptoms in humans, as well as decreased control of asthma symptoms, given sufficient exposure conditions^a^; This judgment is primarily based on studies in residential settings above 0.05 mg/m^3^ and occupational settings at similarly high levels; Potential Susceptibilities: Variation in sensitivity is anticipated depending on respiratory health, physiologic changes during pregnancy, age, and exposure to tobacco smoke. Children are more sensitive than adults.
Human | Strength and Precision | - Strongly elevated risks in occupational settings with exposures from 0.100 to >0.500 mg/m^3^.
Human | Dose-Response | - Although dose-response relationships were not strong within individual studies, a gradient of risk was seen across the sets of studies (see above).
Human | Coherence | - The two studies (one medium and one high confidence) of control of asthma symptoms provide additional support for the effects of formaldehyde exposure among children with asthma at levels at or below those seen in the studies of formaldehyde in relation to the prevalence of asthma. This effect on symptom control is further supported by indirect evidence from a randomized controlled trial.; - The studies of wheezing episodes in infants, particularly the birth cohort studies, are not classified as studies of asthma per se, but could be indicative of respiratory effects with implications for subsequent disease risk. Thus, the associations seen between residential formaldehyde exposure above 0.50 mg/m^3^ and frequency or onset of first wheezing event in these studies provides further indirect support for the body of evidence relating to asthma.
Human | Biological Plausibility | Studies in humans do not provide robust or moderate evidence for mechanistic events that clearly support the development of asthma, although effects in the blood, such as cytokine, cell, and antibody changes, might contribute.
Animal | Experimental animal models are generally considered to be unable to reproduce the overt manifestations of asthma and are not interpreted to provide direct support. | | | Slight; The available animal studies most relevant to evaluating potential effects on asthma and other mechanistic supporting the development of allergic conditions in humans, these same data provide slight animal evidence supportive of effects on asthma.
Animal | Biological Plausibility | - In the same way the available mechanistic data are interpreted to provide slight animal evidence information were interpreted to provide slight animal evidence for an effect.
Other inferences | - Relevance to humans: The primary effect of interest was observed in humans (moderate evidence).; - MOA: Not established, but several incomplete MOAs involving airway inflammatory changes are considered likely to be involved. Regarding the animal mechanistic data, while several events (e.g., amplified bronchoconstriction; eosinophil increases) have an unclear direct linkage to complex human diseases like asthma, these findings inform the potential for exposure to result in changes to relevant neurological and immunological constituents present in both human and rodent airways and are therefore viewed as human relevant.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

### 3.2.4 Respiratory Tract Pathology

This section describes research on formaldehyde inhalation and pathology endpoints in the respiratory system. Of the human studies that met the PECO criteria, one was concluded to be not informative (Berke, 1987) during study evaluation. The study evaluations are included in Appendix B.3.5.

Numerous well-conducted experimental animal studies consistently demonstrate concentration- and, to a lesser extent, duration-dependent URT hyperplasia and metaplasia after formaldehyde exposure. Supporting these observations, a set of four studies in formaldehyde-exposed workers provides consistent findings of an elevated prevalence of nasal lesions such as hyperplasia and metaplasia. The workers were generally exposed to lower levels of formaldehyde than those eliciting changes in experimental animals. While the evidence for both of these nonneoplastic lesions indicates that formaldehyde exposure changes the morphology and function of the URT tissue, the evidence for metaplasia, in particular, is considered to be the best representation of a potential health hazard.

In the URT, both hyperplasia and metaplasia are adaptive tissue responses. These cellular responses help reduce the impact of stressors by changing the structure or function of the locally affected tissue (Harkema et al., 2013). Hyperplasia, generally a response to cell injury, involves an increase in the population of resident cells that results in additional cell layers noticeable by histology, whereas metaplasia, which typically occurs following prolonged or repeated insults, results in the replacement of one differentiated cell type with another more resilient cell type (Harkema et al., 2013). While hyperplasia and metaplasia may also be relevant, but not necessary, to the development of cancer (see Section 3.2.5), they are, by themselves, nonneoplastic lesions. Importantly, metaplasia results in a hardened, drier, and nonciliated skin-like layer (Tomashefski, 2008). Along with the acquisition of a protective, barrier-type phenotype, this metaplastic change causes a loss of normal tissue function, including reduced mucous secretion and ciliary clearance. Thus, this loss of normal function is judged to be an adverse outcome in and of itself (i.e., independent from its potential role in progression to cancer). As an interpretation regarding adversity is less clear for hyperplasia, this discussion emphasizes the data on squamous metaplasia.

Both hyperplasia and metaplasia are typically associated with cellular proliferation (Harkema et al., 2013). As compared to transient increases in cell number, sustained cell proliferation is required for the formation of hyperplasia. This type of change can be precipitated by damage to the nasal epithelium, which is evaluated histologically by measures of, for example, cell loss or necrosis, epithelial degeneration, and erosions. Relatedly, squamous metaplasia is an adaptive response to continued toxic insult that involves cellular substitution. Thus, it is useful to consider these cellular damage-related endpoints in the context of hyperplasia and metaplasia. While evaluations of necrosis- and cytotoxicity-related pathology are informative to this section, these endpoints were generally inconsistently measured or poorly reported across the available studies and are therefore are only summarily discussed. Although hyperplasia and metaplasia might have been underevaluated or underreported for similar reasons (e.g., most studies focus on carcinogenic lesions), the potential development of these lesions appears to have been considered and documented in nearly all the long-term formaldehyde inhalation studies examining URT histopathology.

Studies that evaluated related outcomes, such as mucociliary flow rates, cellular proliferation counts based on DNA labeling, and mucosal swelling, are evaluated in Appendix B.3.6 and summarized in Appendix C.7.1). These types of effects were generally evaluated after acute or short-term exposure and typically represent immediate response repair mechanisms rather than tissue remodeling (e.g., hyperplasia, metaplasia), the latter of which is often a consequence of longer-term exposure or sustained injury. Accordingly, those related outcomes are interpreted to be most relevant to the mechanistic progression of the more overt URT lesions considered in this section, and they are discussed as such in the MOA analysis. Overall, mechanistic insights from the human and animal data indicate a clear role for altered mucociliary function or cellular proliferation in the occurrence of the more overt lesions. Consistent with some of the animal health effect studies, these mechanistic data also suggest that concentration is likely to be more of a driver of these effects than duration (noting that duration still contributes).

Given the large number of long-term exposure studies with information on URT pathology and the focus of the assessment on the effects of lifetime formaldehyde exposure, this section generally focuses on animal studies of subchronic or chronic exposure, and on human studies of occupational exposure where exposed employees were generally employed for longer than 5 years. Exceptions include discussion of shorter-term studies that might inform the potential for relationships between lesion types and studies specifically considering differences in the exposure paradigm (e.g., intermittent versus constant exposures) for lesion induction. Dysplastic lesions and other evidence of carcinogenicity, which are examined in many of the same studies addressed in this section, are discussed in Section 3.2.5.

Overall, the strength of the evidence for hyperplasia and squamous metaplasia includes robust evidence from animal studies and moderate human evidence from observational epidemiology studies, and strong support for a plausible MOA based largely on mechanistic evidence in animals (supported by more limited, coherent findings in human mechanistic studies). Therefore, the evidence demonstrates that inhalation of formaldehyde causes respiratory tract pathology in humans given sufficient exposure conditions. The primary support for this conclusion is based on rat bioassays of chronic exposure, which consistently observed squamous metaplasia at formaldehyde exposure levels ≥2.5 mg/m^3^.

#### Human Studies

A small number of studies were available that reported the results of histological examinations of nasal tissues from formaldehyde-exposed occupational groups. These are described in Table 3-25, organized by publication year. Although the evidence was more equivocal in one study (Boysen et al., 1990), the four medium confidence studies examining histopathology found that exposed participants had a higher average histopathological score than their respective comparison group (Holmstrom et al., 1989c; Edling et al., 1988; Ballarin et al., 1992). Average formaldehyde levels ranged from 0.05 to 0.6 mg/m^3^. These were cross-sectional studies of current workers who may have been less sensitive to the long-term respiratory irritant effects of formaldehyde, which would cause survival bias and an attenuation of comparisons between exposed and comparison groups. Although the studies were limited by probable survival bias, and in some cases, other limitations resulting in a bias toward the null, a consistent association with histopathological endpoints was observed. Edling et al. (1988) did not adjust analyses for differences in smoking prevalence between the exposed and referent groups; smoking prevalence was higher among participants in the referent group. Therefore, the expected effect on the association with formaldehyde exposure would again be toward the null. However, the association observed by Edling et al. (1988) was consistent with those reported by the other studies that did address potential confounding by smoking status. There was no evidence of a time-dependent relationship with formaldehyde. Additionally, there was no indication that coexposure with wood dust or smoking modified the pathological effects of formaldehyde.

The preponderance of evidence shows that the increases in histopathological score levels were due to a high level of squamous metaplasia among participants exposed to formaldehyde levels ranging from 0.1 to 2.5 mg/m^3^. Squamous metaplasia was seen in 32−67% of exposed participants (Edling et al., 1988; Boysen et al., 1990; Ballarin et al., 1992).

Table 3-25

Formaldehyde effects on respiratory pathology in occupational settings

Study and design and exposure | Results
Histological analyses
Ballarin et al. (1992); Italy; Prevalence study; Population: 15 plywood factory workers (mean age 31 years, employment duration 6.8 years) compared to 15 university or hospital clerks matched for age and sex. All nonsmokers.; Exposure: Personal sampling;; 8-hr TWA Kominsky and Stroman (1977); Warehouse (N = 3), 0.39 ± 0.20 mg/m^3^, range 0.21–0.6 mg/m^3^; Shearing-press (N = 8), 0.1 ± 0.02 mg/m^3^, range 0.08–0.14 mg/m^3^; Sawmill (N = 1), 0.09 mg/m^3^; Inspirable wood dust: 0.11–0.69 mg/m^3^, 0.73 in sawmill; Methods: Cytopathology analysis of nasal respiratory mucosa cells blinded by two readers, scoring and classification analogous to Torjussen et al. (1979) and Edling et al. (1988); most severe score present assigned. Mean histological scores exposed compared to referent using Mann-Whitney U test; difference by exposure group for classification of pathology, χ^2^ test.; Evaluation: ^a^; Medium confidence (↓); Inclusion only of current workers raises possibility of healthy worker survival effect due to irritation effects. | Distribution of histological scores of nasal respiratory mucosa cells
| Description | | Exposed | Referent
| Normal | | 0 | 4 (26%)
| Loss of ciliated cells | | 15 (100%) | 10 (67%)
| Hyperplasia | | 6 (40%) | 5 (33%)
| Squamous metaplasia | | 10 (67%)* | 1 (6%)
| Mild dysplasia | | 1 (6%) | 0
| Score (Mean (SD)) | | 2.3 (0.5)* | 1.6 (0.5)
| *Mann-Whitney U test (p < 0.01) or χ^2^ test (p < 0.01)
Boysen et al. (1990); Prevalence survey; Oslo, Norway; Population: 37/74 exposed volunteers from a chemical company producing formaldehyde (50% of exposed workforce). Mean age 51, range 27–66 years. Mean years employed 20, range 3–36 years. 37 age-matched referent subjects without overt nasal disease or occupations associated with nasal cancer. Office staff at two Oslo chemical companies, hospital laboratory personnel, and outpatients at the ear, nose, and throat department of hospital. Mean age 49, range 35–66 years.; Exposure: Systematic formaldehyde monitoring after 1980. Before 1980, exposure assessed by plant health officer with knowledge of the production process, recent measurements, and worker sensations. Range of formaldehyde 0.5 ppm to >2 ppm.; Methods: Scoring and classification of histologic samples per Tojussen, 1979 protocol but on a 0–5-point scale by two authors blinded to clinical or occupational status. Wilcoxon rank sum test used to compare histological findings in the two groups. Χ^2^ test used to compare the rhinoscopical findings and subjective complaints.; Evaluation: ^a^; Medium confidence (↓); Inclusion only of current workers and long duration of employment raises possibility of healthy worker survival effect due to irritation effects. | Rhinoscopy: 75% of exposed workers and 89% of controls had normal mucosa. 24% of the exposed and 8% of the unexposed had hyperplastic nasal mucosa (difference not statistically significant). Degree of metaplastic alterations more pronounced among the exposed workers than in controls (difference not statistically significant).; Higher prevalence of subjective nasal complaints in formaldehyde-exposed workers (43%) compared to 5% in unexposed controls (p < 0.01).
| Distribution of histological scores
| | Description | Exposed | Referent
| 0 | Columnar epithelium | 3 | 5
| 1 | Stratified cuboidal epithelium | 16 | 17
| 2 | Mixed stratified cuboidal/stratified squamous epithelium | 5 | 10
| 3 | Stratified squamous epithelium, nonkeratinizing | 9 | 5
| 4 | Stratified squamous epithelium, keratinizing | 1 | 0
| 5 | Dysplasia | 3 | 0
| | | 1.9/5 | 1.4/5
Holmström and Wilhelmsson (1988); Holmstrom et al. (1989a); Sweden; Prevalence study; Population: Two exposed groups 170 total; 70 formaldehyde production workers, Mean age 36.9 years, 87% male, mean duration employment 10.4 year. 100 workers exposed to wood dust and formaldehyde at five furniture factories. Mean age 40.5 years, 93% male, mean duration employment 16.6 year. Referent: 36 persons from local government in the same village as the furniture workers, with no history of occupational exposure to formaldehyde or wood dust. Mean age 39.8 years, 56% male, mean duration employment 11.4 year.; “Slightly” larger number of smokers in the exposed group than control group, but difference not statistically significant (data not provided).; Exposure: Personal sampling in breathing zone for 1–2 hours in 1985.; Total dust and respirable dust also measured.; Previous measurements 1979–1984 in chemical company combined with 1985 values to estimate average annual values for each participant. Only 1985 values available for wood factories.; Formaldehyde concentration: Chemical Plant: 0.05–0.5 mg/m^3^, mean 0.26 [SD 0.17 mg/m^3^]. Furniture Factory: 0.2–0.3 mg/m^3^, mean 0.25 [SD 0.05 mg/m^3^]. Referent mean 0.09 mg/m^3^ (based on four measurements in four seasons).; Methods: Pretesting questionnaire, histological changes in nasal mucosa graded by a pathologist blind to exposure according to Torjussen et al. (1979) grading scale of 0–8. 2 tailed t-test for group comparisons.; Evaluation: ^a^; Medium confidence (↓); Inclusion of only current workers and long duration of employment raises possibility of healthy worker survival effect due to irritation effects. | Formaldehyde-only nasal specimens had higher mean score of 2.16 (range 0–4) (p < 0.05, comparison to referent) while formaldehyde dust group had mean score of 2.07 (range 0–6) (p > 0.05, comparison to referent). Referent group score was 1.56 (range 0–4). Combining formaldehyde-only and formaldehydedust group mean score of 2.11 (p < 0.05). No correlation observed between smoking habits and biopsy score, nor was a correlation found between the duration of exposure and any histological changes.
Edling et al. (1987a, 1988); Prevalence Study; Sweden; Population: 75 of 104 exposed male factory workers from three plants (2 particle board plants and one laminae-processing). Mean duration of employment: 10.5 years. Mean age: 38 years; range 22–63 years. 35% smokers and 9% ex-smokers. Referents: 25 men with similar age and smoking habits and no known industrial exposures to formaldehyde. Mean age: 35 years, range 25–60. 48% smokers and 10% ex-smokers.; Exposure: Past TWA formaldehyde measurements made by plant industrial hygienists sporadically between 1975 and 1983. Levels of formaldehyde in air ranged from 0.1 to 1.1 mg/m^3^, with peaks up to 5 mg/m^3^. No measurements available before 1975 but estimated levels higher during the 1960s and early 1970s. Particle board plants contained low concentrations of wood dust at 0.6–1.1 mg/m^3^.; Methods: Nasal mucosa histological grading by pathologist blinded to exposure using Torjussen et al. (1979) grading system with 0–8 ranking.; Compared differences in nasal mucosa histological score using Wilcoxon nonparametric test.; Evaluation: ^a^; Medium confidence (↓); Inclusion of only current workers and long duration of employment (mean 10.5 years) and high prevalence of symptoms raises possibility of healthy worker survival. | Prevalence in exposed of normal nasal mucosa, 75%; prevalence swollen or dry or both changes, 25%. Histological scores higher in exposed compared to referents, mean 2.9 vs. 1.8; (p < 0.05) (Wilcoxon). No association with years of exposure.
| Histological scores in exposed ^a^
| Characteristics | Score | # | %
| Normal respiratory epithelium | 0 | 3 | 4
| Loss of ciliated cells | 1 | 8 | 11
| Mixed cuboid/squamous epithelium, metaplasia | 2 | 24 | 32
| Stratified squamous epithelium | 3 | 18 | 24
| Keratosis | 4 | 16 | 21
| Budding of epithelium | 5 | 0 | 0
| Mild or moderate dysplasia | 6 | 6 | 8
| Severe dysplasia | 7 | 0 | 0
| Carcinoma | 8 | 0 | 0
| ^a^Data for referent group were not reported

Organized by study confidence, then descending publication year.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.5. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Summary of Human Evidence Synthesis Judgments

The following factors, primarily the consistency across occupational studies, were influential to the synthesis judgment that the human studies on respiratory tract pathology provide moderate evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: Three of four of the available medium confidence studies, all occupational, observed a higher prevalence of abnormal nasal histopathology with higher formaldehyde exposure.
- Biological Plausibility: Although sparse, evidence in humans shows effects of relatively high formaldehyde exposure (≥ 0.25 mg/m^3^) on nasal mucociliary function.

#### Animal Studies

A large database of well-designed studies has characterized formaldehyde-induced respiratory tract pathology in mice, hamsters, and monkeys, but primarily in rats. The durations of these studies range from a few hours to longer than 2 years, and several studies included recovery periods that explored the reversibility of lesions. While a few studies include the examination of tissues in other areas of the respiratory tract, most studies focus on pathology in the nasal mucosa. This synthesis focuses on the incidence of hyperplasia and metaplasia formed after inhaled formaldehyde exposure. To the extent the available data allow, the discussion separately addresses the lesion locations along the URT and specifically within the nasal mucosa, the influence of concentration and exposure duration on lesion formation and lesion persistence, and sex and species differences in pathology. Because of the abundance of studies that evaluated respiratory tract pathology, only those studies judged to be of high and medium confidence (see Appendix B.3.5) are presented in detail in the synthesis and evidence tables below. Note that unlike some other sections, this includes well-performed formalin studies. Thus, this section does not synthesize the studies that met the PECO criteria but were classified as not informative (Yorgancilar et al., 2012; Schreiber et al., 1979; Ohtsuka et al., 1997; Murta et al., 2016; Lima et al., 2015; Ionescu et al., 1978; Holmstrom et al., 1989b; Coon et al., 1970; Casanova et al., 1994; Bhalla et al., 1991; Bansal et al., 2011; Arican et al., 2009), nor those studies classified as low confidence (Monticello et al., 1996; Kamata et al., 1996; Horton et al., 1963; Chang et al., 1983; Buckley et al., 1984).

Likewise, as animal studies of effects from long-term exposure are most pertinent to lifetime human exposure, and because some of these lesions can be very slow to develop, long-term studies (preferably ≥52 weeks of exposure and follow-up) were generally considered to be more informative. Accordingly, evidence tables of the experimental animal studies are organized by study duration, with chronic and subchronic respiratory pathology studies ordered according to species, study confidence, and descending publication year in Tables 3-26 and 1-27, respectively. Short-term studies, generally ≤1−4 weeks long, are sometimes discussed in the synthesis, but are only described in detail if they provide insights unavailable in the longer-term studies, specifically those including information on species differences or the relationship between the concentration and duration dependency of lesion formation (see Table 3-28; see Appendix C.6.1 for evidence tables of the other short-term studies). Some studies reported multiple endpoints (e.g., pathological effects and cell proliferation), which were individually considered. Studies that reported URT pathology-related mechanistic information relevant to interpreting the progression of events leading to overt respiratory tract pathology (see Appendix B.3.6 and C.7), including cell proliferation and mucociliary function, are discussed as mechanistic information informing MOA.

Nasal lesions (i.e., cytotoxicity, hyperplasia, and metaplasia) have been consistently reported in multiple rodent species and strains, and in monkeys. For hyperplasia and metaplasia, there were consistent indications of a concentration-response, and to a somewhat lesser extent, exposure duration-dependent relationships with inhaled formaldehyde. Somewhat surprisingly, multiple studies report that metaplasia appeared to be more sensitive, prevalent, or extensive than hyperplasia (sometimes pronounced metaplasia was observed in the absence of hyperplasia), reducing support for a strictly sequential progression of these lesions. The most informative data on squamous metaplasia (i.e., from long-term medium or high confidence studies), which is considered to be an adverse effect independent of its potential role in cancer progression, are illustrated in Figures 3-14 and 3-15.

Figure 3-14 Squamous metaplasia in medium and high confidence chronic and subchronic respiratory pathology studies of inhaled formaldehyde

Studies are organized by study evaluation confidence (see Appendix B.3.5), species, and then duration of exposure. Shading is indicated as follows: black = statistically significant effects, as indicated by study authors; gray = increases in incidence in studies without statistical analyses, with dark gray indicating pronounced changes (incidences of 50–100% were noted for many of these groups) and light gray indicating subtle changes (generally <25% change compared to controls); see Tables 3-26 through 3-28. Exposure groups with larger sample sizes are depicted as larger circles. Abbreviations: Syr. G. = Syrian golden; ht = heterozygotes; Sub. = subchronic; M + F = male and female; wk = week, mos = months, yr = year.

Figure 3-15 Squamous metaplasia incidence in high and medium confidence rat studies of chronic and subchronic formaldehyde exposure duration

Incidence data for squamous metaplasia (i.e., of any severity) from the high and medium confidence studies with ≥1 year of formaldehyde exposure (Panel A, chronic exposure) or with ≥3 months of exposure (Panel B, subchronic exposure). Symbols for chronic studies are outlined in black, while subchronic studies are outlined in gray. In addition, high confidence studies include black fill, while medium confidence studies are filled in either white or a combination of white and gray. The size of the points reflects sample size for that particular exposure group (i.e., larger size = larger n). Notes: this figure does not present statistical significance; data points at 24.2 mg/m3 (Woutersen et al., 1987) and 24.6 mg/m3 (Feron et al., 1988) formaldehyde are not shown (the incidence of squamous metaplasia was approximately 100% at these levels).

##### Anatomical location of lesions in the upper respiratory tract

As previously mentioned, the majority of evidence for formaldehyde exposure-induced pathology in the URT of experimental animals is confined to the nasal cavity, which is discussed in greater detail in the sections below. This focus on the nasal cavity can be explained, at least in part, by the historical interest in nasal carcinogenesis.

The evidence for lesions beyond the nasal cavity in rats suggests that concentration is an important variable in long-term studies. Laryngeal lesions, including hyperplasia and squamous metaplasia, were observed in Sprague Dawley rats exposed to 18.2 mg/m^3^ for a lifetime (Sellakumar et al., 1985) and in male Wistar rats exposed to 24.4 mg/m^3^, but not to ≤11.9 mg/m^3^, for 13 weeks (Woutersen et al., 1987). Tracheal lesions (metaplasia and hyperplasia) were reported in F344 rats after chronic exposure to 17.6 mg/m^3^ formaldehyde (Kerns et al., 1983). Similar results were observed in Sprague Dawley rats in a single concentration (18.2 mg/m^3^) lifetime study (Sellakumar et al., 1985). However, no laryngeal or tracheal lesions were observed in rats exposed to 11.6 mg/m^3^ for 1 year (Appelman et al., 1988).

As reported in three studies, even higher concentrations of inhaled formaldehyde may be necessary for effects beyond the nose in mice. Histopathological changes were not observed in the trachea or lungs of B6C3F1 mice exposed to 17.6 mg/m^3^ for 104 weeks in a study that did not provide quantitative incidence or severity information (Kerns et al., 1983), nor in the larynx of mice exposed to up to 18.5 mg/m^3^ for 8 weeks and evaluated at 1 year (Morgan et al., 2017). However, a subchronic formalin study observed increases in metaplasia and hyperplasia in the trachea at ≥25.1 mg/m^3^ and in the lung at ≥49.6 mg/m^3^ (Maronpot et al., 1986). These high-concentration changes were also observed in a low confidence study with limited severity information that observed squamous metaplasia and hyperplasia in the tracheobronchial epithelium of C3H mice exposed to ≥50 mg/m^3^ for 35 weeks (Horton et al., 1963).

While it is difficult to draw mechanistic inferences with confidence, these studies suggest that, in rodents, high levels of formaldehyde might be necessary to exceed the ability of the nose to scrub formaldehyde from inhaled air and allow formaldehyde to reach sites farther down the respiratory tract, which would be consistent with rodent toxicokinetic data (Appendix C.1).

Somewhat in contrast to the rodent studies, a single medium confidence study in rhesus monkeys, which failed to report lesion severity or incidence, observed a loss of goblet cells, hyperplasia, and metaplasia in the larynx, trachea, and carina, but not in the lungs, after exposure for ≤6 weeks to 7.4 mg/m^3^ formaldehyde (Monticello et al., 1989). This might suggest that the monkey nose is less efficient than the rodent nose at scrubbing formaldehyde from inhaled air.

Overall, the evidence supports the potential for lesions in the larynx and trachea of rats at sustained high formaldehyde concentrations and in rhesus monkeys at sustained moderate concentrations. These findings are particularly interesting in the context of future research into anatomical lesion location following formaldehyde inhalation in nonrodent animal models. The remainder of this section will highlight the far more robust evidence of respiratory tract pathology localized to the nasal cavity.

##### Duration dependency of nasal lesions

Data from exposed rats, supported by findings in other species, identify a clear relationship between formaldehyde exposure duration and the development of squamous metaplasia and, to a lesser extent, hyperplasia. These lesions appear to be at least partially reversible after exposure ceases (see Tables 3-26 through 3-28 for study details).

As shown in Figure 3-16, the nasal cavities of monkeys and rats are lined with four types of epithelia—squamous, transitional, respiratory, and olfactory—and there are unique structures that may be susceptible to pathological change (Young, 1981; Renne and Gideon, 2006; Renne et al., 2009; Monticello et al., 1989; Harkema et al., 2006). Due to the high reactivity and water solubility of formaldehyde, nasal metaplasia and hyperplasia have primarily been assessed (and subsequently observed) in the epithelium lining the anterior regions of rodent nasal passages (typically Levels I, II, and III) following formaldehyde inhalation exposure, mostly in regions containing respiratory epithelium.

Figure 3-16 The four epithelial cell populations that line the nasal lateral wall in monkeys and rats are portrayed in this image

The cell populations are SE = squamous epithelium, TE = transitional epithelium, RE = respiratory epithelium, OE = olfactory epithelium. Note that considerably more olfactory epithelium (OE) lines the intranasal surface in rats than in monkeys. Other abbreviations used in this image are NALT = nasal-associated lymphoid tissue, et = ethmoturbinate, mt = maxilloturbinate, nt = nasoturbinate, na = naris, it = incisor tooth, B = brain.

Source: Harkema et al. (2006).

###### Squamous metaplasia

Squamous metaplasia has been observed to occur after chronic, subchronic, and short-term exposure to inhaled formaldehyde. Overall, the most robust responses (i.e., higher incidence or severity at lower formaldehyde concentrations) occur following chronic exposure.

Multiple chronic rat studies have reported robust increases in squamous metaplasia following exposures of approximately 2.5−2.7 mg/m^3^ (Kerns et al., 1983; Kamata et al., 1997; Battelle, 1982) or 11.3−11.6 mg/m^3^ (Woutersen et al., 1989; Appelman et al., 1988), although some data suggest that slight increases might be present at lower levels (i.e., 0.4−1.2 mg/m^3^) (Woutersen et al., 1989; Kamata et al., 1997). In studies that compared changes in respiratory and olfactory epithelia (Woutersen et al., 1989; Appelman et al., 1988), squamous metaplasia was observed almost exclusively in the respiratory epithelium, except perhaps at the highest formaldehyde levels and with the longest exposure durations [i.e., slight increase in metaplasia at 12.1 mg/m^3^ after 28 months of exposure in Woutersen et al. (1989)]. With subchronic exposure, squamous metaplasia is observed in rat noses at higher concentrations (i.e., ≥11.3 mg/m^3^) in high confidence studies by Appelman et al. (1988), Woutersen et al. (1987), and Feron et al. (1988), the results of which are supported by consistent observations in two medium confidence studies (Zwart et al., 1988; Andersen et al., 2010), although these latter studies observed increases at lower exposure levels (i.e., 2.5−3.7 mg/m^3^). With short-term exposures ranging from 4.4 to 18.4 mg/m^3^, observations of squamous metaplasia in rats across several studies with various methodological limitations provide supporting evidence (Wilmer et al., 1987; Speit et al., 2011; Cassee and Feron, 1994; Andersen et al., 2008), although some findings were not completely consistent with a straightforward duration-dependency (e.g., Andersen et al. (2008) observed squamous metaplasia with 5 days of exposure, but not with shorter or longer exposure durations, at 7.4 mg/m^3^).

The duration-dependency of these lesions in rat studies also appears to be reflected by the locations at which lesions develop, as well as their severity, possibly in parallel with the increases resulting from increasing formaldehyde concentration (see additional discussion below). The association with lesion location is demonstrated by the results of Kerns et al. (1983) which showed that, in anterior nasal regions (i.e., Level I and II) of F344 rats exposed to ≥2.5 mg/m^3^, the incidence of squamous metaplasia increased from ≤20 to 100% with increasing duration (i.e., 6−24 months); however, in posterior nasal regions (i.e., Levels III−V), a duration-dependent increase in incidence was only observed at 17.6 mg/m^3^ (Battelle, 1982). In some instances, noted by Kerns et al. (1983), more posterior lesions were entirely unique to longer exposure durations as compared to shorter exposures (e.g., Level III at 6.9 mg/m^3^ only with 24 months of exposure). Regarding severity, squamous metaplasia was observed to increase (i.e., from slight focal lesions to metaplasia with keratinization) with exposure duration increases from 13 to 52 weeks of exposure to 11.6 mg/m^3^ in Wistar rats (Appelman et al., 1988). Similarly, at ≥11.6 mg/m^3^ in Wistar rats, an increase in the severity of squamous metaplasia in respiratory epithelium occurred as exposure duration increased from 4–8 to 13 weeks (Feron et al., 1988), and at very high formaldehyde levels (24.2 mg/m^3^), exposure duration was associated with an increase in the severity of focal replacement of olfactory epithelium with respiratory epithelium.

Several studies in rats confirm the important role of exposure duration in lesion development by demonstrating that the increases in lesions observed with longer-term exposure, as compared to shorter-term exposure, were not attributable to longer latencies after formaldehyde exposures began in the studies of longer-term exposure (i.e., since metaplasia, in particular, is expected to take several weeks to months to develop). In these studies of Wistar rats, nasal lesions including metaplasia and hyperplasia were consistently investigated at approximately 2 years of age following formaldehyde exposures of different durations (which began at the same ages, thus requiring longer periods of nonexposure in the shorter-term studies) (Woutersen et al., 1989; Feron et al., 1988). When animal ages at evaluation and formaldehyde exposure levels were matched, comparisons of subchronic exposure to chronic exposure (Woutersen et al., 1989) and of short-term exposure to subchronic exposure (Feron et al., 1988) revealed greater incidences or severity of these lesions with the longer exposure durations.

Rodent species other than rats also exhibit squamous metaplasia, although the duration-dependence of these lesions has not been as well established. Additionally, compared to rats, other laboratory rodents may require higher levels (i.e., mice) or exhibit a substantially reduced response (i.e., hamsters), suggesting that there may be differences in species sensitivity to formaldehyde-induced squamous metaplasia. Following chronic exposure, slight increases in the number of mice with metaplasia were observed at 6.9 mg/m^3^, with more pronounced changes at 17.6 mg/m^3^ (Kerns et al., 1983); however, the incidence and severity of these lesions were not quantified. Similarly, in a subchronic formalin study, squamous metaplasia was observed in all mice exposed to 12.4 mg/m^3^ (Maronpot et al., 1986). Two strains of p53 deficient mice (Trp53 heterozygotes) also developed pronounced metaplasia at both tested concentrations (i.e., 9.23 and 18.45 mg/m^3^) after only 8 weeks of exposure (Morgan et al., 2017), with changes that were dose dependent and exhibited an anterior-to-posterior gradient, similar to findings in rats. Squamous metaplasia was observed only in 5% of Syrian golden hamsters exposed to 12.3 mg/m^3^ for a lifetime (Dalbey, 1982), and no changes were observed after subchronic exposure to 3.6 mg/m^3^ in the same strain (Rusch et al., 1983), although these studies did not provide lesion severity.

Although the few available monkey studies did not report detailed endpoint information, squamous metaplasia was observed at 3.6 mg/m^3^ in cynomolgus monkeys following subchronic, near-constant exposure (i.e., 22 hours/day for 7 day/week), and in rhesus monkeys after short-term (i.e., 1 or 6 weeks) exposure to 7.4 mg/m^3^ (Monticello et al., 1989). The latter study in rhesus monkeys also supports the findings in rats of an anterior-to-posterior gradient of lesions with increasing exposure duration, and the general susceptibility of respiratory epithelium. After exposure to 7.4 mg/m^3^ for 1 week, mild squamous metaplasia was observed in the respiratory epithelium of anterior regions (i.e., primarily Level A, the nasal atrium, but also including Levels B and C); however, with exposure to the same concentration for 6 weeks, the lesions were more developed and had progressed to more posterior regions of the nasal cavity (i.e., regions of olfactory epithelium close to the olfactory/respiratory epithelial interface, and including Levels D and E) (Monticello et al., 1989). In another study (Rusch et al., 1983), monkeys exposed to formalin for 26 weeks had both squamous metaplasia and hyperplasia (these lesions were reported together) in the middle region of the nasal turbinates, with incidences of 17% at 0.23 mg/m^3^ and 100% at 3.6 mg/m^3^. No exposure-related effects were reported for the anterior and posterior nasal turbinates.

Although uncertainties remain, the reversibility of metaplasia may depend more on formaldehyde concentration than the duration of exposure. In general, increases in squamous metaplasia incidence appeared to be a persistent effect at higher levels of exposure (i.e., >11 mg/m^3^ in rats and >9 mg/m^3^ in mice), as these lesions were observed many months after formaldehyde exposure in rat recovery study comparisons by Woutersen et al. (1989) and Feron et al. (1988), and in two transgenic mouse strains (Morgan et al., 2017). However, it appears that the magnitude of this effect, particularly at lower formaldehyde levels (e.g., ≤6.9 mg/m^3^), decreases with a recovery period, as evidenced by significant declines in the incidences of squamous metaplasia (and rhinitis) in F344 rats and B6C3F1 mice 3 or 6 months after 24 months of exposure (Kerns et al., 1983; Battelle, 1982).

In summary, experimental studies, primarily in rats, have demonstrated that formaldehyde exposure duration clearly influences the incidence, severity, or anatomical location of squamous metaplasia.

###### Hyperplasia

As with metaplasia, hyperplasia of the nasal epithelium has been observed across various durations of exposure. In some studies, hyperplasia was reported as a concurrent lesion with metaplasia (Rusch et al., 1983; Reuzel et al., 1990; Kamata et al., 1997; Cassee and Feron, 1994).

Reliable results from several studies show that chronic formaldehyde exposure of approximately 11.6−12.1 mg/m^3^ induces hyperplasia in the nasal epithelium of rats (Woutersen et al., 1989; Appelman et al., 1988). Studies with more limited endpoint information also reported the formation of hyperplasia following exposure to 7.4−18.2 mg/m^3^ (Sellakumar et al., 1985; Monticello et al., 1996). Subchronic exposure to formaldehyde also leads to hyperplasia in rat nasal passages after exposure to 11.9 mg/m^3^ (Woutersen et al., 1987) and after exposure to approximately 3.7 mg/m^3^ as reported in two studies with limited endpoint information (Zwart et al., 1988; Rusch et al., 1983). Following short-term exposures in rats to 4.4−18.5 mg/m^3^, studies with methodological shortcomings also report the formation of nasal epithelium hyperplasia (Wilmer et al., 1987; Chang et al., 1983; Cassee and Feron, 1994; Andersen et al., 2008), adding support. While in nearly all cases, hyperplasia was observed in respiratory or transitional epithelium (or, in a few cases, isolated regions of olfactory epithelium), a single medium confidence, short-term study reported that after 4 weeks of exposure to 18.4 mg/m^3^, hyperplasia of the epithelium surrounding NALT (nasal-associated lymphoid tissue) was observed in a majority (87.5%) of F344 rats, but not B6C3F1 mice (Kuper et al., 2011). Overall, comparisons of the formaldehyde concentrations at which significant increases in hyperplasia are observed across studies of differing exposure duration do not provide a clear picture of the potential duration dependence of formaldehyde-exposure-induced hyperplasia.

However, like the results for metaplasia, several rat studies comparing exposures of differing exposure duration (e.g., chronic versus subchronic) demonstrate that increasing exposure duration results in increases in the incidence and/or severity of hyperplasia in the respiratory epithelium when testing the same formaldehyde concentrations and anatomical levels (Woutersen et al., 1989; Kerns et al., 1983; Feron et al., 1988; Appelman et al., 1988). This included two high confidence studies matching the age of the animals at assessment (Woutersen et al., 1989; Feron et al., 1988) to allow identical amounts of time for lesions to develop after the exposures began. Similarly, some data also indicate that duration can influence the location of the observed hyperplasia, with an increased frequency of lesions in more posterior locations (i.e., at more posterior nasal levels or in more posterior structures, such as the trachea) with longer-term exposure (Woutersen et al., 1989; Kerns et al., 1983). However, in the identified rat studies, the within-study increases in incidence or posterior location with comparatively longer exposures were generally only observed at high levels of formaldehyde (i.e., >10 mg/m^3^), preventing clear interpretations regarding the duration dependence of hyperplasia at lower formaldehyde levels.

The role for duration in the development of hyperplasia in other laboratory animal species is less clear. Hyperplasia was reported in a chronic mouse study with limited endpoint information following exposure to 2.5 mg/m^3^ (Kerns et al., 1983), with consistent findings in a low confidence, short-term study at 18.5 mg/m^3^ (Chang et al., 1983); however, a medium confidence, short-term study in transgenic mice failed to observe significant increases in hyperplasia after exposure to 9.23–18.5 mg/m^3^, despite the presence of pronounced metaplasia (Morgan et al., 2017). Interestingly, however, this short-term mouse study did observe increases in nasal osteogenesis (evidence of bone proliferation in the nasal turbinates) at 18.45 mg/m^3^ in both strains tested (Morgan et al., 2017). In a lifetime study by Dalbey (1982), 5% of hamsters had hyperplasia following exposure to 12.3 mg/m^3^; however, hyperplasia did not appear to develop in hamsters exposed to 3.6 mg/m^3^ for 26 weeks, although hyperplasia was not specified (i.e., the authors reported no treatment-related histopathology) (Rusch et al., 1983). In cynomolgus monkeys, hyperplasia along with metaplasia was reported following subchronic exposure to 3.6 mg/m^3^ (Rusch et al., 1983), and hyperplasia was also found in rhesus monkeys exposed to 7.4 mg/m^3^, although lesion incidence or severity was not reported (Monticello et al., 1989). When specified, the hyperplasia observed in mice (Kerns et al., 1983) and rhesus monkeys (Monticello et al., 1989) was generally identified in the anterior nose.

Hyperplasia in rats and mice appears to persist, at least in part (Woutersen et al., 1989; Kerns et al., 1983; Feron et al., 1988; Battelle, 1982), as with observations of squamous metaplasia. However, hyperplasia generally appears to be more reversible than metaplasia, even at higher formaldehyde concentrations, as evidenced by smaller increases in incidence with a prolonged recovery following exposure to ~11 mg/m^3^ formaldehyde (Woutersen et al., 1989; Feron et al., 1988). Findings in a short-term recovery study in rats (Andersen et al., 2008), with similar results observed in a low confidence study in mice (Chang et al., 1983), suggest that hyperplasia may take some small amount of time to develop, as lesions progressed in incidence or severity with 18 hours of recovery after very brief (i.e., days) exposures.

Taken together, formaldehyde exposure duration does appear to have some influence on the development of hyperplasia, primarily based on studies in rats. However, considering the notable influence of exposure duration on metaplasia at formaldehyde levels ranging from 2.5 to 2.7 mg/m^3^ in rat studies (Kerns et al., 1983; Kamata et al., 1997), the easier reversibility of hyperplasia, as well as the generally more robust effects of duration on the incidence of metaplasia as compared to hyperplasia across species, exposure duration appears to be more important to the development of metaplasia in laboratory animals than to the development of hyperplasia. Overall, uncertainties remain regarding the relative impact of duration on the development of hyperplasia (particularly in species other than rats), as compared to the pronounced role for concentration, particularly at low formaldehyde levels (see additional discussion below).

###### Necrosis, nasal damage, and cytotoxicity

Although possessing methodological limitations, numerous short-term studies and three long-term studies in rats report overt damage to the nasal epithelium following exposure to 3.9−7.4 mg/m^3^ (Cassee and Feron, 1994; Cassee et al., 1996; Andersen et al., 2010), 12 mg/m^3^ (Wilmer et al., 1987), or approximately 18.5 mg/m^3^ (Speit et al., 2011; Chang et al., 1983), with supporting evidence from ultrastructural analyses in a short-term study (Monteiro-Riviere and Popp, 1986). Consistent observations of nasal tissue damage were reported in rhesus monkeys (Monticello et al., 1989) and in a low confidence, mouse study with methodological limitations (Chang et al., 1983) following short-term exposure to ≥7.4 mg/m^3^. In rhesus monkeys (Monticello et al., 1989), loss of cilia and goblet cells was more severe and covered a greater surface of respiratory epithelium (including extranasal respiratory tract regions), as duration of exposure increased. As these observations of tissue cytotoxicity generally appear to occur following exposures of shorter duration than in many of the studies reporting metaplasia or hyperplasia at similar formaldehyde concentrations, these data may be consistent with the evolution of hyperplasia and metaplasia from other lesions with increasing exposure duration.

##### Concentration dependency of nasal lesions

The development of nasal lesions in rodents and monkeys has routinely been shown to exhibit a strong concentration dependency in terms of incidence, frequency, severity, and location of the observed lesions. This is particularly true for both squamous metaplasia and hyperplasia in the respiratory epithelium. Importantly, several studies have reported the occurrence of metaplasia in the absence of hyperplasia at a given exposure level (see Tables 3-26 and 3-27 for study details).

###### Squamous metaplasia

Although there is a demonstrated exposure duration dependency for the development of squamous metaplasia, formaldehyde concentration appears to be at least as important, if not more so. With increasing formaldehyde concentration, squamous metaplasia is observed in more posterior regions of the nasal tissue, and there is a marked increase in both lesion incidence and severity.

In a chronic study reporting metaplasia throughout the rat nasal passage (Kerns et al., 1983; Battelle, 1982), metaplasia was observed in the anterior nose (i.e., Level I) after exposure to 2.5 mg/m^3^ and progressed in incidence toward the posterior nose, reaching Level V only after exposure to 17.6 mg/m^3^. Consistent observations of the anterior-to-posterior progression of metaplasia with increasing exposure concentration were reported by another high confidence chronic study (Woutersen et al., 1989). These findings are supported by results from a low confidence chronic study with limited endpoint reporting (Monticello et al., 1996), as well as by medium confidence subchronic (Andersen et al., 2010) and short-term (Speit et al., 2011) studies.

With a constant duration of exposure, concentration-dependent increases for metaplasia in rat noses (Level II) after 24 months were reported in a chronic study where 1.1, 62.2, and 100% of rats were observed to have squamous metaplasia after exposure to 2.5, 6.9, or 17.6 mg/m^3^, respectively (Kerns et al., 1983; Battelle, 1982). Additional studies provide support for a concentration-dependent increase in squamous metaplasia incidence following chronic and subchronic exposures in rats and mice (Woutersen et al., 1989; Maronpot et al., 1986; Kamata et al., 1997; Feron et al., 1988; Andersen et al., 2010). The incidence of squamous metaplasia and hyperplasia (lesions were reported together) also increased with concentration in rats and cynomolgus monkeys (Rusch et al., 1983).

The severity of metaplasia (e.g., from very slight to severe) also increased with concentration, as reported by subchronic studies (Woutersen et al., 1987; Feron et al., 1988; Andersen et al., 2010) and a short-term study with a relatively small sample size (Speit et al., 2011). In general, while concentration-dependent increases in more mild instances of metaplasia are typically observed at concentrations of 2.5 mg/m^3^ and above (see previous section), moderate or severe lesions were only observed at the highest formaldehyde concentrations (approximately 12 mg/m^3^ or more). The available studies demonstrate that formaldehyde exposure concentration occupies a central role in the development of squamous metaplasia.

###### Hyperplasia

Concentration-dependent increases in the incidence and severity of hyperplasia have also been observed in rats with chronic, subchronic, or short-term exposure durations (Woutersen et al., 1989; Kamata et al., 1997; Appelman et al., 1988; Andersen et al., 2008) and with subchronic exposure in F344 rats and cynomolgus monkeys (Rusch et al., 1983). Overall, the concentration dependence of these lesions, in terms of location, incidence, and severity, closely paralleled the pattern of changes observed for squamous metaplasia, identifying a strong influence of exposure concentration on the development of hyperplasia.

###### Necrosis, nasal damage, and cytotoxicity

Results for concentration-dependent cytotoxicity are varied, as reported by less-than-chronic studies. A subchronic study observed no concentration-dependent increase in necrosis in the noses of Wistar rats exposed to 1.2 or 2.5 mg/m^3^ for 13 weeks (Wilmer et al., 1989). Following ≤13 weeks of exposure to 0.8−18.5 mg/m^3^, however, the incidence of necrosis/erosions in F344 noses generally increased with concentrations of 7.4 mg/m^3^ and greater (Andersen et al., 2010). Following 4 weeks of formalin exposure from 0.63 to 18.4 mg/m^3^, degeneration was observed only after exposure to the highest concentration in F344 rats (Speit et al., 2011), while focal thinning and epithelial disarrangement of the respiratory epithelium was observed in Wistar rats exposed to ≥12 mg/m^3^ (Wilmer et al., 1987).

##### Studies comparing potential differential contributions of duration and concentration

Several animal respiratory pathology studies employed designs that compared intermittent and continuous exposure scenarios to examine the extent to which Haber’s rule (C × t = K; where C is concentration, t is time, and K is a constant) applies to formaldehyde-induced nasal pathology. If, for example, Haber’s rule can be strictly applied, similar pathological lesions should result whether rats are exposed to 12 mg/m^3^ for 3 hours (12 × 3 = 36) or to 6 mg/m^3^ for 6 hours (6 × 6 = 36).

Wilmer et al. (1987) and Wilmer et al. (1989) used continuous and intermittent exposure scenarios to assess whether lesion formation appears to be influenced more by concentration or duration of exposure. In Wilmer et al. (1987), male rats were exposed to formaldehyde 5 days/week for 4 weeks. Groups of rats were either continuously exposed for 8 hours/day to target concentrations of 0, 6, or 12 mg/m^3^ formaldehyde, or intermittently exposed (30 minutes of exposure followed by 30 minutes of nonexposure) to 0, 12, or 25 mg/m^3^ formaldehyde (the analytical concentrations were not reported). Thus, the weekly inhaled concentrations (concentration × hours × days) were the same for the continuous and intermittent exposure groups: 0, 240, or 480 mg/m^3^-hour/week. The main difference was that the intermittently exposed rats were exposed to higher concentrations than the continuously exposed rats. The rats exposed intermittently to the higher concentrations (12 or 25 mg/m^3^) had greater nasal cell proliferation and histopathologic lesions, including squamous metaplasia and basal cell hyperplasia, than did the rats exposed continuously to the lower concentrations (6 or 12 mg/m^3^).

Similar results were seen in a 13-week study (Wilmer et al., 1989) in which groups of male rats were either continuously exposed for 8 hours/day to target concentrations of 0, 1, or 2 mg/m^3^ formaldehyde, or intermittently exposed (30 minutes of exposure followed by 30 minutes of nonexposure) to 0, 2, or 5 mg/m^3^ formaldehyde (again, the analytical concentrations were not reported). The rats exposed continuously had greater incidences of diffuse disarrangement, diffuse necrosis, focal and diffuse basal cell hyperplasia, focal squamous metaplasia, keratinization, and diffuse goblet cell hyperplasia than the rats exposed intermittently. For some of these lesions, the incidences were greater in the rats exposed continuously to 2 mg/m^3^ than to 5 mg/m^3^, the interpretation of which is unclear. Overall, the Wilmer et al. studies suggest that in rats exposed for 4 or 13 weeks the extent of nasal lesions and cell proliferation appears to be driven more by concentration than by duration of exposure or cumulative dose. These findings are consistent with changes in cell proliferation reported in an acute and a short-term study using similar approaches (Wilmer et al., 1987; Swenberg et al., 1983); (see Appendix C.7.1).

While the authors of another subchronic rat study reached similar conclusions, the data did not fully support a clear concentration over duration driver for the observed effects. Rusch et al. (1983) compared the findings in their 6-month rat study against the 6-month exposure phase in the 2-year rat study by Kerns et al., as reported in the supporting report by Battelle for CIIT (Kerns et al., 1983; Battelle, 1982). Rusch et al. (1983) exposed animals 22 hours/day, 7 days/week for a total of 154 hours/week, compared to 6 hours/day, 5 days/week in the (Kerns et al., 1983; Battelle, 1982) study, for a total of 30 hours/week; that is, the rats in the Rusch et al. (1983) study were exposed five times longer than in the (Kerns et al., 1983; Battelle, 1982) study. At 6 months, squamous metaplasia was observed at 2.5 mg/m^3^ by (Kerns et al., 1983; Battelle, 1982) versus at 3.6 mg/m^3^ in the Rusch et al. (1983) study. However, the incidence was ~60% at 3.6 mg/m^3^ in Rusch et al. (1983), as compared to only 20% at 2.5 mg/m^3^ in the (Kerns et al., 1983; Battelle, 1982) study. In addition, while (Kerns et al., 1983; Battelle, 1982) did not test lower formaldehyde levels, metaplasia incidence went from 2/38 in controls to 3/36 at 1.2 mg/m^3^ in Rusch et al. (1983), introducing the possibility that the study may have been inadequately powered to detect an effect at lower levels. Regardless, these data do support the possibility of an increased dependence on concentration, as compared to duration, as the rats in Rusch et al. (1983) did not appear to be five-fold more sensitive.

In summary, several rat studies suggest that formaldehyde, perhaps similar to mortality responses following acute exposure to some other local irritants, may not adhere strictly to Haber’s rule for the induction of nasal pathology. Although duration of exposure has a clear and substantial role for the development of these nasal lesions (see discussion above), the experiments by Wilmer et al. (1987) and Wilmer et al. (1989) suggest that a power-law function (C^n^ × t = K) where n is >1 may better represent formaldehyde exposure-induced nasal lesions than the linear C × t = K, at least when interpreting short-term or subchronic exposure (the exposure scenarios examined by Wilmer et al.). Although a value for n was not identified for formaldehyde, or for exposure-induced nasal pathology, in particular, studies of acute exposure to other local irritants and the concentration-duration dependence for mortality suggest that the value for n, on average, is approximately 1.8−1.9 (ranging from 0.5 to 4.0).^22^ It is difficult to speculate where within this range a value for n might be most applicable to formaldehyde, particularly within the context of respiratory pathology and long-term exposures (i.e., since these n values are for mortality after acute exposure); however, based on the data discussed in previous sections, it might be reasonable to expect that an n defined for associations with hyperplasia should be higher than one defined for metaplasia.

##### Species and sex differences in respiratory pathology

While most respiratory pathology studies have been conducted in rats, studies conducted with mice, hamsters, and monkeys have reported interspecies differences in susceptibility (i.e., lesion incidence and severity), and in the location of lesions. Additionally, differences between sexes of the same species have also been observed.

Rats have consistently been shown to be more susceptible than mice to the formation of various nasal lesions after chronic, subchronic, and short-term exposures. A well-conducted bioassay exposing F344 rats and B6C3F1 mice to 2.5, 6.9, or 17.6 mg/m^3^ formaldehyde for 24 months reported that squamous metaplasia was observed in rat noses at all exposure levels, whereas in mice metaplasia was only observed after exposure to the intermediate and high concentrations. Additionally, lesions observed in mice were less severe than in rats at the same concentration level. In fact, similar incidences of squamous cell carcinoma were observed in rats exposed at 6.9 mg/m^3^ and in mice exposed at 17.6 mg/m^3^ (Kerns et al., 1983). Likewise, Kuper et al. (2011) observed hyperplasia of the NALT lymphoepithelium in rats, but not in mice. A possible explanation for these species disparities is that mice have a greater reflex bradypnea response than rats and thus inhaled lower doses of formaldehyde than rats. Unfortunately, minute volume and body temperature were not measured in the 2-year Battelle study or in Kuper et al. (2011), so there is no way of knowing whether reflex bradypnea played a significant role (see Appendix C.2 for a discussion on reflex bradypnea).

Rats also show differences with other species. Rats, and, to a lesser extent, mice, appear to be more sensitive than Syrian hamsters (Rusch et al., 1983; Dalbey, 1982; Appelman et al., 1988). The comparisons to nonrodent experimental models are less clear. Squamous metaplasia and hyperplasia were specifically found in the anterior, middle, and posterior nasal turbinates of F344 rats, but lesions were predominantly in the middle nasal turbinates of cynomolgus monkeys (Rusch et al., 1983) and rhesus monkeys (Monticello et al., 1989). Monticello et al. (1989) observed lesions that extended to proximal regions of the URT (outside of the nasal cavity) at lower concentrations than in the rat studies (7.4 mg/m^3^, as compared to >15 mg/m^3^), likely because the monkey nose is less efficient than the rodent nose at scrubbing formaldehyde from inhaled air.

In addition to differences between species, the formation of histopathological lesions was sometimes observed to differ between sexes, although most studies only examined male animals. A subchronic study in Wistar rats reported that males generally had more severe damage, including metaplasia, to the nasal respiratory, olfactory epithelium, and larynx (Woutersen et al., 1987). Supportive findings of increased incidence or severity of lesions in males as compared to females was also reported in a second subchronic study of Wistar rats (Zwart et al., 1988), as well as in mouse studies of subchronic (Maronpot et al., 1986) and chronic (Kerns et al., 1983; Battelle, 1982) duration. Male rats have a higher metabolic rate and oxygen demand than female rats, and therefore greater minute volumes; thus, these findings might also reflect a greater inhaled dose of formaldehyde in males as compared to females at the concentrations tested.

Table 3-26 Chronic respiratory pathology studies in animals

Reference and study design | Results
Rats
High confidence
Woutersen et al. (1989); Wistar rats; male; 30/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for 3 or 28 months. All survivors sacrificed at 28 months.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.1 (±0.07), 1.2 (±0.22), or 11.3 (±2.0) mg/m^3^ for 3month exposures and 0, 0.1 (±0.05), 1.2 (±0.14), or 12.1 (±1.60) mg/m^3^ for 28-month exposures.^1^; Histopathology: 6 standard cross sections of the nose.; Note: This study also evaluated the effects of FA in a parallel group of rats that had undergone bilateral electrocoagulation (i.e., damaged nose group) prior to the initiation of FA exposure). Data presented here in the Results column are for FA-only (i.e., undamaged nose group) exposed rats. | 3 months of exposure followed by a 25-month observation period with no exposure:
| FA-related histological changes generally not observed for Levels IV–VI.
| Histopathological nasal changes after 3 months of exposure and 25-month recovery period
| | Incidence of lesions in Levels I–II
| | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 11.3 mg/m^3^
| Type of lesions (Severity NR)
| Respiratory epithelium
| Disarrangement | 0/26^a^ | 0/30 | 0/29 | 1/26
| Squamous metaplasia | 3/26 | 6/30 | 4/29 | 17/26
| Keratinization | 0/26 | 0/30 | 1/29 | 2/26
| Basal cell/pseudoepithelial hyperplasia | 1/26 | 0/30 | 0/29 | 4/26
| Nest-like infolds/goblet cell hyperplasia | 11/26 | 3/30 | 15/29 | 9/26
| Invaginations | 3/26 | 0/30 | 0/29 | 0/26
| Rhinitis | 5/26 | 4/30 | 3/29 | 13/26
| Olfactory epithelium
| Thinning/disarrangement | 0/26 | 0/30 | 0/29 | 0/26
| Basal cell hyperplasia | 0/26 | 0/30 | 0/29 | 0/26
| Vacuolation/proteinaceous material/numeric atrophy | 0/26 | 0/30 | 0/29 | 0/26
| Replaced by respiratory epithelium | 0/26 | 0/30 | 0/29 | 0/26
| ^a^Denominator represented by the effective number of animals and not the initial number of animals.
| Large variation observed for nest-like infolds/goblet cell hyperplasia; due to lack of exposure-response, this change was not considered to be exposure-related.
| 28 months of exposure:
| 12.1 mg/m^3^―Incidence of rhinitis elevated in Level I–VI; other FA-related histological changes in respiratory epithelium generally found in Level II and III; lesions observed in olfactory epithelium in Levels III and IV.
| Histopathological nasal changes after 28 months of exposure period
| | Incidence of lesions in Levels I–II
| | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 12.1 mg/m^3^
| Type of lesions (Severity NR)
| Respiratory epithelium
| Disarrangement | 0/26^a^ | 0/26 | 1/28 | 1/26
| Squamous metaplasia | 3/26 | 1/26 | 6/28 | 25/26
| Keratinization | 0/26 | 1/26 | 0/28 | 2/26
| Basal cell/pseudoepithelial hyperplasia | 0/26 | 1/26 | 2/28 | 14/26
| Nest-like infolds/goblet cell hyperplasia | 5/26 | 6/26 | 14/28 | 4/26
| Invaginations | 0/26 | 0/26 | 1/28 | 3/26
| Rhinitis | 2/26 | 1/26 | 2/28 | 18/26
| Olfactory epithelium
| Thinning/disarrangement | 0/26 | 0/26 | 0/28 | 0/26
| Squamous metaplasia | 0/26 | 0/26 | 0/28 | 0/26
| Basal cell hyperplasia | 0/26 | 0/26 | 0/28 | 0/26
| Vacuolation/proteinaceous material/numeric atrophy | 0/26 | 0/26 | 0/28 | 0/26
| Replaced by respiratory epithelium | 0/26 | 0/26 | 0/28 | 0/26
| ^a^Denominator represented by the effective number of animals and not the initial number of animals.
| Highest incidence for nest-like infolds/goblet cell hyperplasia observed for Level II at 1.2 mg/m^3^; due to lack of exposure-response, this change was not considered to be exposure-related.
| 28 months of exposure (continued):
| Histopathological nasal changes after 28 months of exposure period
| | Incidence of lesions in Level III
| | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 12.1 mg/m^3^
| Type of lesions (Severity NR)
| Respiratory epithelium
| Disarrangement | 4/26^a^ | 0/26 | 2/28 | 1/26
| Squamous metaplasia | 0/26 | 0/26 | 0/28 | 13/26
| Keratinization | 0/26 | 0/26 | 0/28 | 1/26
| Basal cell/pseudoepithelial hyperplasia | 1/26 | 0/26 | 2/28 | 7/26
| Nest-like infolds/goblet cell hyperplasia | 1/26 | 2/26 | 2/28 | 1/26
| Invaginations | 0/26 | 0/26 | 0/28 | 0/26
| Rhinitis | 1/26 | 0/26 | 2/28 | 6/26
| Olfactory epithelium
| Thinning/disarrangement | 1/26 | 1/26 | 1/28 | 7/26
| Squamous metaplasia | 0/26 | 0/26 | 0/28 | 2/26
| Basal cell hyperplasia | 3/26 | 3/26 | 4/28 | 3/26
| Vacuolation/proteinaceous material/numeric atrophy | 1/26 | 1/26 | 3/28 | 0/26
| Replaced by respiratory epithelium | 0/26 | 0/26 | 1/28 | 2/26
| ^a^Denominator represented by the effective number of animals and not the initial number of animals.
Kerns et al. (1983); Fischer 344 rats; males and females; 119 to 121/sex/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for up to 24 months. Animals sacrificed at 27 and 30 months had 3- and 6-month periods of nonexposure, respectively, after 24-months of exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0, 2.5 (±0.01), 6.9 (±0.02), or 17.6 (±0.05) mg/m^3^.^a^; Histopathology: 5 midsagittal sections of nasal turbinates (Levels I–V; see Figure 3-14) for all animals that died or were sacrificed at scheduled intervals (i.e., at month 6, 12, 18, 24, 27, and 30).; Related studies/earlier reports: Swenberg et al. (1980a); Battelle (1981, 1982). See Battelle, 1982 for a more detailed study report.; Note: transient viral infection at 52 weeks was noted, but considered unlikely to influence these findings. | | | Pathological changes^a,b^
| Exposure duration | | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| 6 months | | NR^c^ | Levels I, II, and III: purulent rhinitis, epithelial dysplasia, and squamous metaplasia observed | Lesions first noted in anterior sections (Levels I, II, and III) of nose; changes in epithelium restricted to ventral portion of nasal septum and distal tips of nasoturbinates and maxilloturbinates
| 12 months | | Level I^d^: purulent rhinitis, epithelial dysplasia, and squamous metaplasia observed | Levels I, II, and III: purulent rhinitis, epithelial dysplasia, and squamous metaplasia observed | NR
| 18 months | | NR | Levels I, II, and III: purulent rhinitis, epithelial dysplasia, and squamous metaplasia observed | NR
| 24 months | | Frequency of metaplasia exceeded that of prior sacrifices; dysplasia and metaplasia only observed in Level I | Levels I, II, and III: purulent rhinitis, epithelial dysplasia, and squamous metaplasia observed | NR
| 27 months^e^ | | Significant decrease (p < 0.05) in frequency of metaplasia | Levels I, II, and III: regression (p < 0.05) of squamous metaplasia | Levels IV and V: regression (p < 0.05) of squamous metaplasia
| ^a^Severity of lesions most intense in Level I for all exposure groups. Exposure-related effects observed in Levels II, III, IV, and V for 6.9- and 17.6-mg/m^3^ groups. Lesion frequency in exposed groups greater than the <15% lesion frequency observed for 0 mg/m^3^ group, where lesions (e.g., dysplasia and metaplasia) only present in Level I.
| ^b^Authors defined squamous metaplasia as zones of altered epithelium characterized by a well-differentiated germinal cell layer (stratum germinativum) and superficial epithelial layers (stratum spinosum and stratum corneum). Authors further noted that keratin was only produced in areas of squamous metaplasia, and that in all exposure groups epithelial dysplasia was detected earlier than squamous metaplasia.
| ^c^Chart nine of Kerns et al. (1983) provides graphical representation of the frequency of squamous metaplasia observed for Levels I–V for all exposure groups during 24-month exposure and 3-month nonexposure period.
| ^d^At this location, authors observed a transition in the mucosa from normal nonciliated simple cuboidal epithelium to an epithelial lining several cells thick and squamoid in appearance. The organization and polarity of the individual epithelial cells changed from vertical to horizontal with respect to the basement membrane. The authors termed such alterations as zones of epithelial dysplasia and noted that similar histomorphological alterations have been called basal cell hyperplasia and epidermoid metaplasia.
| ^e^24 months of exposure and 3 months of nonexposure.
| General observations (respiratory epithelium):
| | 17.6 mg/m^3^―squamous metaplasia with zones of squamous epithelial hyperplasia and increased keratin production appeared to precede area of squamous papillary hyperplasia with foci of cellular atypia; dyspnea and death caused by excessive accumulation of keratin and inflammatory exudate in lumen of nasal cavity of rats (with and without carcinomas).
| General observations (tracheal pathology):
| | 17.6 mg/m^3^―rats (frequency NR) sacrificed at 18 months exhibited multifocal areas of mild epithelial hyperplasia, epithelial dysplasia, or squamous metaplasia of proximal tracheal mucosa; similar lesions at a greater frequency (p < 0.05) observed in rats from 24-month sacrifice and unscheduled death groups; tracheal lesions not observed in postexposure group.; 0, 2.5, or 6.9 mg/m^3^―no significant tracheal lesions observed
| Incidence of squamous metaplasia in nasal cavity of rats
| Level I^a^
| Duration | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| 6 months | NA^b^ | 4/20 | 10/20 | NA
| 12 months | NA | 7/20 | 11/20 | NA
| 18 months | 0/40 | 24/40 | 35/40 | 38/39
| 24 months | 1/101 | 91/94 | 81/82 | 27/27
| 27 months^d^ | 3/19 | 4/20^c^ | 8/19^c^ | 5/5
| 30 months | 1/10 | 2/5 | 1/8 | NR
| Level II
| 6 months | NA | 0/20 | 10/20 | NA
| 12 months | NA | 0/20 | 8/20 | NA
| 18 months | 0/40 | 0/40 | 24/40 | 38/39
| 24 months | 0/101 | 1/94 | 51/82 | 27/27
| 27 months | 0/19 | 0/20 | 5/19^c^ | 5/5
| 30 months | 0/10 | 0/5 | 5/8 | NR
| Level III
| 6 months | 0/20 | 0/20 | 0/20 | 6/20
| 12 months | 0/20 | 0/20 | 0/20 | 10/20
| 18 months | 0/40 | 0/40 | 0/40 | 38/39
| 24 months | 0/101 | 0/94 | 9/82 | 26/27
| 27 months | 0/19 | 0/20 | 0/19 | 4/5
| 30 months | 0/10 | 0/5 | 0/8 | NR
| Level IV
| 6 months | NA | 0/20 | 0/20 | NA
| 12 months | NA | 0/20 | 0/20 | NA
| 18 months | 0/40 | 0/40 | 0/40 | 14/39
| 24 months | 0/101 | 0/94 | 1/82 | 21/27
| 27 months | 0/19 | 0/20 | 0/19 | 1/5^c^
| 30 months | 0/10 | 0/5 | 0/8 | NR
| Level V
| 6 months | NA | 0/20 | 0/20 | NA
| 12 months | NA | 0/20 | 0/20 | NA
| 18 months | 0/40 | 0/40 | 0/40 | 11/39
| 24 months | 0/101 | 0/94 | 0/82 | 19/27
| 27 months | 0/19 | 0/20 | 0/19 | 0/5^c^
| 30 months | 0/10 | 0/5 | 0/8 | NR
| ^a^Data reported in part in Kerns et al. (1983) and further adapted from Battelle (1982)^b^ tissue section not available for histopathology; ^c^p < 0.05, regression of squamous metaplasia 3 months postexposure; ^d^data for 27 and 30 months represent incidence after 3 and 6 months of nonexposure, respectively, following 24 months of exposure.
Medium confidence
Kamata et al. (1997); Fischer 344 rats; male; 32/group.; Exposure: Rats were exposed to FA in dynamic nose-only chambers 6 hours/day, 5 days/week for 28 months with interim sacrifices at the end of months 12, 18, and 24.; Test article: Formalin (37% FA aqueous solution containing 10% methanol).; Actual concentrations were 0, 0.40 (±0.09), 2.67 (±0.40), or 18.27 (±2.73) mg/m^3^.^a^ The concentration of methanol in the 0 and 18.27 groups was estimated to be 5.5 mg/m^3^.^b^ A room control served as a no exposure group.; Histopathology: nasal region (sections from five anatomical levels, A-E; see Figure 3-14) and trachea.; Main limitations: formalin; small N for interim sacrifices; lesion severities NR | Group | Squamous cell metaplasia no epithelial cell hyperplasia | Epithelial cell hyperplasia with squamous cell metaplasia | Epithelial cell hyperkeratosis | Papillary hyperplasia
| Room control | No nasal lesions observed | No nasal lesions observed | No nasal lesions observed | No nasal lesions observed
| 0 mg/m^3^; (5.5 mg/m^3^ MeOH) | No nasal lesions observed | No nasal lesions observed | No nasal lesions observed | No nasal lesions observed
| 0.40 mg/m^3^ | 1/32^a^; (1/5 at 18-month) | 4/32; (1/5 at 24-month, 3/11 at 28-month) | No nasal lesions observed | No nasal lesions observed
| 2.67 mg/m^3^ | 5/32^b^; (2/5 at 18-month, 1/5 at 24-month, 2/7 at 28-month) | 7/32^c^; (2/5 at 18-month, 1/7 at 28-month, 4/10 of dead) | 1/32; (1/10 of dead) | No nasal lesions observed
| 18.27 mg/m^3^; (5.5 mg/m^3^ MeOH) | NR | 29/32^c^; (3/5 at 12-month, 4/5 at 18-month, 2/2 at 24-month, 20/20 of dead) | 29/32^c^; (4/5 at 12-month, 1/5 at 18-month, ½ at 24-month, 20/20 of dead) | 2/32; (2/5 at 12-month)
| ^a^data reported as group total (i.e., dead animals plus scheduled sacrifices at 12, 18, 24, and 28 months); number in parenthesis represent incidence at sacrifice; ^b^p < 0.05, compared to 0 mg/m^3^ group; ^c^p < 0.01, compared to 0 mg/m^3^ group
Appelman et al. (1988); SPF Wistar rat; male; 20/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for 52 weeks. Half of the rats in each group were sacrificed at 13 weeks.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.1 (±0.05), 1.2 (±0.18), or 11.6 (±1.60) mg/m^3^.^a^ Histopathology: nose (6 standard cross levels), larynx, trachea, and lungs.; Main limitations: small N; limited reporting of lesion severity (note: this 12-month study was shorter than the other available chronic studies).; Note: This study also evaluated the effects of FA in a parallel group of rats that had undergone bilateral electrocoagulation 20 to 26 hours prior to the initiation of FA exposure (not shown). | Histopathological nasal changes after 13 weeks of exposure (data included for comparison with 52 weeks of exposure)
| Type of lesion | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 11.6 mg/m^3^
| Respiratory epithelium
| Focal squamous metaplasia:
| Slight | 0/10 | 0/10 | 1/10 | 9/10^a^
| Moderate/severe | 0/10 | 0/10 | 0/10 | 1/10
| Focal basal cell hyperplasia:
| Slight | 0/10 | 0/10 | 0/10 | 7/10^a^
| Moderate/severe | 0/10 | 0/10 | 0/10 | 0/10
| Focal rhinitis | 0/10 | 0/10 | 0/10 | 6/10^b^
| Nest-like infolds | 0/10 | 0/10 | 0/10 | 0/10
| Olfactory epithelium
| Focal thinning/disarrangement | 0/10 | 0/10 | 0/10 | 0/10
| Focal basal cell hyperplasia | 0/10 | 0/10 | 0/10 | 0/10
| Focal rhinitis | 0/10 | 0/10 | 0/10 | 0/10
| ^a^p < 0.01; ^b^p < 0.05
| Histopathological nasal changes after 52 weeks of exposure
| Type of lesion | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 11.6 mg/m^3^
| Respiratory epithelium
| Squamous metaplasia
| Focal | 0/10 | 0/10 | 0/10 | 6/10^a^
| Diffuse | 0/10 | 0/10 | 0/10 | 0/10
| Keratinization | 0/10 | 0/10 | 0/10 | 5/10^a^
| Basal cell hyperplasia
| Focal | 0/10 | 0/10 | 0/10 | 5/10^a^
| Diffuse | 0/10 | 0/10 | 0/10 | 5/10^a^
| Focal rhinitis | 2/10 | 0/10 | 0/10 | 10/10^a^
| Nest-like infolds
| Focal | 6/10 | 2/10 | 3/10 | 4/10
| Diffuse | 2/10 | 4/10 | 3/10 | 0/10
| Olfactory epithelium
| Thinning/disarrangement | 1/10 | 0/10 | 0/10 | 3/10
| Focal basal cell hyperplasia | 0/10 | 0/10 | 0/10 | 2/10
| Focal squamous metaplasia | 0/10 | 0/10 | 0/10 | 0/10
| Loosely arranged submucosal connective tissue | 0/10 | 0/10 | 0/10 | 0/10
| Focal rhinitis | 0/10 | 0/10 | 0/10 | 0/10
| ^a^p < 0.05
| Histopathological changes in larynx, trachea, and lungs were those commonly found in this strain of rat and were about equally distributed among controls and exposed groups or were only found in one rat; these changes ultimately characterized as unrelated to FA exposure.
Sellakumar et al. (1985); Sprague Dawley rats; male; 100/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for life.; Test article: Paraformaldehyde.; Actual concentrations were 0 and 18.2 (±2.6) mg/m^3^.^a^; Histopathology: multiple (interpreted as ≥ 5 based on study description) sections of the head (from just behind the nostril to the eye orbits) as well as sections of lung (each lobe), trachea, and larynx.; Preliminary study: Albert et al. (1982); Main limitations: likely coexposure to paraffin oil (kerosene); lesion severities NR | Observation | | | 0 mg/m^3^ | 18.2 mg/m^3^
| Larynx
| Hyperplasia | | | 2/99 | 21/100
| Squamous metaplasia | | | 0/99 | 4/100
| Trachea
| Hyperplasia | | | 6/99 | 21/100
| Squamous metaplasia | | | 0/99 | 7/100
| Nasal Mucosa
| Rhinitis (mild to severe) | | | 72/99 | 74/100
| Epithelial or squamous hyperplasia | | | 51/99 | 57/100
| Squamous metaplasia | | | 5/99 | 60/100
| Additional observations (frequencies NR) from FA exposures included: exudation in the nasal cavity lumen; necrosis; desquamation of respiratory epithelial cells of respiratory epithelial covering of naso-maxillary turbinates and nasal septum; and inflammation of olfactory epithelium lining the ethmoidal turbinates, with seropurulent exudate in lumen.
Mice
Medium confidence
Kerns et al. (1983); B6C3F1 mice; males and females; 119 to 121/sex/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for up to 24 months. Animals sacrificed at 27 and 30 months had 3- and 6-month periods of nonexposure, respectively, after 24-months of exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0, 2.5 (±0.01), 6.9 (±0.02), or 17.6 (±0.05) mg/m^3^.^a^; Histopathology: 5 midsagittal sections of nasal turbinates corresponding to the regions evaluated in rats in this study (levels I–V; see Figure 3-14) for all animals that died or were sacrificed at scheduled intervals (i.e., at month 6, 12, 18, 24, 27, and 30).; Earlier reports: Battelle (1981); Battelle (1982); Main limitations: high mortality in all groups; limited sampling (i.e., sections); lesion incidence and severity NR | | Pathological changes^a^
| Exposure duration | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| 12 mos | ND | ND | Serous rhinitis in Levels III and V
| 18 mos | ND | Few mice^c^ had dysplastic changes associated with serous rhinitis in Level II | ^~^90% of mice had dysplastic and metaplastic alterations of nasal mucosa in Level II with a serous to purulent change in nasal exudate
| 24 mos | Few animals had serous rhinitis in Level II, but no significant nasal lesions; hyperplasia (minimal to moderate) of squamous epithelium lining nasolacrimal duct | Few mice had dysplasia, metaplasia, or serous rhinitis in Level II; hyperplasia (minimal to moderate) of squamous epithelium lining nasolacrimal duct; focal atrophy of olfactory epithelium lining the ethmoturbinates | >90% of mice had dysplastic and metaplastic changes associated with seropurulent rhinitis; hyperplasia (minimal to moderate) of squamous epithelium lining nasolacrimal duct, greatest frequency and distribution found in this FA level; focal atrophy of olfactory epithelium lining the ethmoturbinates, greatest frequency at this FA level
| 27 mos^b^ | FA-related lesions ND | FA-related lesions ND; regression observed for squamous metaplasia and rhinitis for all affected Levels | Dysplastic epithelial lesions with serous exudate observed; squamous metaplasia in Level II in (^~^20% of mice), but not in Levels III and IV; regression observed for squamous metaplasia and rhinitis for all affected Levels
| ^a^Unless noted, severities NR; ^b^24 months of exposure and 3 months of nonexposure; ^c^Unless noted, exact frequency of lesion NR.; No tracheal lesions were observed.
Hamsters
Medium confidence
Dalbey (1982); Syrian golden hamsters; male; 132 untreated controls and 88 exposed.; Exposure: Hamsters were exposed to FA in dynamic whole-body chambers 5 hours/day, 5 days/week for a lifetime.; Test article: Paraformaldehyde.; Actual FA concentrations were 0 and 12.3 (±5%) mg/m^3^.^a^; Histopathology: 2 transverse sections of the nasal turbinates, longitudinal sections of larynx and trachea, and all lung lobes cut along the bronchus.; Main limitations: lesion severities NR; Note: this study also evaluated the effects of FA on tumorigenicity of diethylnitrosamine (DEN), either from concurrent exposures or from DEN then FA exposures (not shown). | Hamsters exposed at 12.3 mg/m^3^ had slightly reduced survival (p < 0.05) relative to controls.
| Nasal epithelium:
| | Hyperplastic lesions; 12.3 mg/m^3^−4/88 (5%); 0 mg/m^3^−0/132; Metaplastic lesions; 12.3 mg/m^3^−4/88 (5%); 0 mg/m^3^−0/132; Rhinitis; 12.3 mg/m^3^−21/88 (24%); 0 mg/m^3^−41/132 (31%)

Organized by species, confidence, and then descending publication year. As discussed above, results from low confidence studies are not included given the many high and medium confidence studies (see Appendix B. 3.5).

Abbreviations: FA = formaldehyde, NA = not available, ND = not detected, NR = not reported, SD = standard deviation.

a Study authors originally reported FA concentrations in ppm. These values were converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

b Study authors did not report methods for specific methanol measurements but appeared to estimate the concentration based on the proportion of methanol in the formalin solutions to determine their control group methanol concentrations (see Section 2 on assessment methods and organization for relevant discussion of the uncertainties related to this assumption). Study authors originally reported methanol concentrations in ppm. These methanol values were converted based on 1 ppm = 1.31 mg/m^3^.

Table 3-27 Subchronic respiratory pathology studies in animals

Reference and study design | Results
Rats
High confidence
Feron et al. (1988); Wistar rats; male; 45/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers; 6 hours/day, 5 days/week for either 4, 8, or 13 weeks followed by nonexposure periods of 126, 122, or 117 weeks, respectively.; Test article: Paraformaldehyde.; Actual concentrations were 0, 11.3 (±0.25), or 24.2 (±0.12) mg/m^3^ for the 4-week exposed groups; 0, 11.6 (±0.21), or 24.2 (±0.11) mg/m^3^ for the 8-week exposed groups; and 0, 11.9 (±0.15), or 24.4 (±0.09) mg/m^3^ for the 13-week exposed groups.^a^; Histopathology: 6 standard cross levels of the nose.; Note: only tested high formaldehyde levels | 4 weeks of exposure followed by observation period of 126 weeks
| | | | | | Incidence of lesions
| | | | | | 0 mg/m^3^ | | 11.3 mg/m^3^ | | 24.2 mg/m^3^
| Focal hyperplasia of respiratory epithelium
| Very slight | | | | | 0/44 | | 0/44 | | 0/45
| Slight | | | | | 0/44 | | 3/44 | | 8/45^c^
| Moderate | | | | | 0/44 | | 0/44 | | 1/45
| Focal stratified squamous metaplasia of respiratory epithelium
| Very slight | | | | | 3/44 | | 6/44 | | 14/45^c^
| Slight | | | | | 4/44 | | 2/44 | | 19/45^c^
| Moderate | | | | | 0/44 | | 2/44 | | 3/45
| Severe | | | | | 0/44 | | 0/44 | | 0/45
| Rhinitis | | | | | 7/44 | | 7/44 | | 18/45^b^
| Simple or stratified cuboidal or squamous metaplasia of epithelium in the dorsomedial area where respiratory and olfactory epithelium join^a^ | | | | | 0/44 | | 0/44 | | 4/45
| Focal replacement of olfactory epithelium by respiratory, respiratory-like or regenerating olfactory epithelium
| Very slight | | | | | 0/44 | | 0/44 | | 0/45
| Slight | | | | | 1/44 | | 0/44 | | 6/45
| Moderate | | | | | 0/44 | | 0/44 | | 1/45
| Severe | | | | | 0/44 | | 0/44 | | 0/45
| ^a^The changes in this area were scored separately because their origin from either respiratory or olfactory epithelium was not clear; ^b^p < 0.05; ^c^p < 0.01
| 8 weeks of exposure followed by observation period of 122 weeks
| | | | | | Incidence of lesions
| | | | | | 0 mg/m^3^ | | 11.6 mg/m^3^ | | 24.2 mg/m^3^
| Focal hyperplasia of respiratory epithelium
| Very slight | | | | | 0/45 | | 1/44 | | 3/43
| Slight | | | | | 2/45 | | 2/44 | | 12/43^c^
| Moderate | | | | | 0/45 | | 1/44 | | 0/43
| Focal stratified squamous metaplasia of respiratory epithelium
| Very slight | | | | | 8/45 | | 16/44 | | 17/43^b^
| Slight | | | | | 2/45 | | 1/44 | | 20/43^c^
| Moderate | | | | | 0/45 | | 0/44 | | 2/43
| Severe | | | | | 0/45 | | 0/44 | | 0/43
| Rhinitis | | | | | 4/45 | | 6/44 | | 22/43^b^
| Simple or stratified cuboidal or squamous metaplasia of epithelium in the dorsomedial area where respiratory and olfactory epithelium join | | | | | 0/45 | | 0/44 | | 17/43^c^
| Focal replacement of olfactory epithelium by respiratory, respiratory-like or regenerating olfactory epithelium
| Very slight | | | | | 0/45 | | 0/44 | | 2/43
| Slight | | | | | 0/45 | | 0/44 | | 14/43^b^
| Moderate | | | | | 0/45 | | 0/44 | | 3/43
| Severe | | | | | 0/45 | | 0/44 | | 1/43
| ^a^See above for explanation; ^b^p < 0.05; ^c^p < 0.01
| 13 weeks of exposure followed by observation period of 117 weeks
| | | | | | Incidence of lesions
| | | | | | 0 mg/m^3^ | | 11.9 mg/m^3^ | | 24.4 mg/m^3^
| Focal hyperplasia of respiratory epithelium
| Very slight | | | | | 0/45 | | 5/44^b^ | | 2/44
| Slight | | | | | 1/45 | | 6/44 | | 14/44^c^
| Moderate | | | | | 0/45 | | 0/44 | | 4/44
| Focal stratified squamous metaplasia of respiratory epithelium
| Very slight | | | | | 2/45 | | 10/44^b^ | | 2/44
| Slight | | | | | 3/45 | | 18/44^c^ | | 26/44^c^
| Moderate | | | | | 1/45 | | 5/44 | | 14/44^c^
| Severe | | | | | 0/45 | | 0/44 | | 1/44
| Rhinitis | | | | | 8/45 | | 11/44 | | 23/44^c^
| Simple or stratified cuboidal or squamous metaplasia of epithelium in the dorsomedial area where respiratory and olfactory epithelium join^a^ | | | | | 0/45 | | 2/44 | | 23/44^c^
| Focal replacement of olfactory epithelium by respiratory, respiratory-like or regenerating olfactory epithelium
| Very slight | | | | | 0/45 | | 0/44 | | 1/44
| Slight | | | | | 0/45 | | 0/44 | | 12/44^c^
| Moderate | | | | | 0/45 | | 0/44 | | 12/44^c^
| Severe | | | | | 0/45 | | 0/44 | | 1/44
| ^a^See above for explanation; ^b^p < 0.05; ^c^p < 0.01
Woutersen et al. (1987); Wistar rats; male and female; 10/sex/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers for 6 hours/day, 5 days/week for 13 weeks.; Test article: Paraformaldehyde.; Actual concentrations were 0, 1.2 (±0.00), 11.9 (±0.15), or 24.4 (±0.09) mg/m^3^.^a^; Histopathology: sections of the lungs, trachea, larynx (3 longitudinal) and nose (6 standard cross sections). | [Males] Histological changes in the nose at 13 weeks
| | | | Incidence of lesions
| | | | 0 mg/m^3^ | | 1.2 mg/m^3^ | | 11.9 mg/m^3^ | | 24.4 mg/m^3^
| Respiratory epithelial squamous metaplasia
| Diffuse
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 5/10^a^
| Severe | | | 0/10 | | 0/10 | | 0/10 | | 5/10^a^
| Focal
| Very slight | | | 0/10 | | 1/10 | | 0/10 | | 0/10
| Slight | | | 0/10 | | 1/10 | | 6/10^a^ | | 0/10
| Moderate | | | 0/10 | | 0/10 | | 4/10 | | 0/10
| Focal respiratory epithelial hyperplasia
| Very slight | | | 0/10 | | 0/10 | | 1/10 | | 1/10
| Slight | | | 0/10 | | 0/10 | | 6/10^a^ | | 7/10^b^
| Moderate | | | 0/10 | | 0/10 | | 1/10 | | 0/10
| Focal respiratory epithelial disarrangement
| Very slight | | | 0/10 | | 0/10 | | 1/10 | | 0/10
| Slight | | | 0/10 | | 0/10 | | 3/10 | | 0/10
| Moderate | | | 0/10 | | 0/10 | | 1/10 | | 0/10
| Focal respiratory epithelial keratinization
| Very slight | | | 0/10 | | 2/10 | | 6/10^a^ | | 1/10
| Slight | | | 0/10 | | 0/10 | | 3/10 | | 6/10^a^
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 1/10
| Focal olfactory epithelial thinning
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 1/10
| Severe | | | 0/10 | | 0/10 | | 0/10 | | 5/10^a^
| Focal olfactory epithelial squamous metaplasia
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 4/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 4/10
| Olfactory epithelial keratinization
| Very slight | | | 0/10 | | 0/10 | | 0/10 | | 1/10
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Rhinitis | | | 0/10 | | 2/10 | | 5/10^a^ | | 10/10^b^
| Slight submucosal loosely arranged connective tissue | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Pharyngeal duct mononuclear cell infiltrate | | | 9/10 | | 10/10 | | 10/10 | | 8/10
| Nasolachrymal duct sinusitis | | | 3/10 | | 6/10 | | 7/10 | | 2/10
| Maxillary sinus sinusitis | | | 7/10 | | 3/10 | | 4/10 | | 2/10
| ^a^p < 0.05; ^b^p < 0.01
| [Females] Histological changes in the nose at 13 weeks
| | | | Incidence of lesions
| | | | 0 mg/m^3^ | | 1.2 mg/m^3^ | | 11.9 mg/m^3^ | | 24.4 mg/m^3^
| Respiratory epithelial squamous metaplasia
| Diffuse
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 3/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 4/10
| Severe | | | 0/10 | | 0/10 | | 0/10 | | 3/10
| Focal
| Very slight | | | 0/10 | | 0/10 | | 1/10 | | 0/10
| Slight | | | 0/10 | | 1/10 | | 7/10^b^ | | 0/10
| Moderate | | | 0/10 | | 0/10 | | 2/10 | | 0/10
| Focal respiratory epithelial hyperplasia
| Very slight | | | 0/10 | | 0/10 | | 2/10 | | 1/10
| Slight | | | 0/10 | | 1/10 | | 6/10^a^ | | 6/10^a^
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Focal respiratory epithelial disarrangement
| Very slight | | | 0/10 | | 0/10 | | 2/10 | | 1/10
| Slight | | | 0/10 | | 1/10 | | 6/10^a^ | | 6/10^a^
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Focal respiratory epithelial keratinization
| Very slight | | | 0/10 | | 0/10 | | 6/10^a^ | | 6/10^a^
| Slight | | | 0/10 | | 0/10 | | 2/10 | | 4/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Focal olfactory epithelial thinning
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Severe | | | 0/10 | | 0/10 | | 0/10 | | 2/10
| Focal olfactory epithelial squamous metaplasia
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 3/10
| Moderate | | | 0/10 | | 0/10 | | 0/10 | | 1/10
| Olfactory epithelial keratinization
| Very slight | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Slight | | | 0/10 | | 0/10 | | 0/10 | | 0/10
| Rhinitis | | | 0/10 | | 0/10 | | 3/10 | | 2/10
| Slight submucosal loosely arranged connective tissue | | | 0/10 | | 0/10 | | 0/10 | | 4/10
| Pharyngeal duct mononuclear cell infiltrate | | | 10/10 | | 10/10 | | 10/10 | | 10/10
| Nasolachrymal duct sinusitis | | | 3/10 | | 5/10 | | 2/10 | | 4/10
| Maxillary sinus sinusitis | | | 1/10 | | 1/10 | | 5/10 | | 0/10
| ^a^p < 0.05; ^b^p < 0.01
| Lung:; - Histological changes (e.g., focal accumulation of alveolar macrophages) in the lung were considered not to be exposure related but as common findings in this strain and rat age.; Larynx:; - Squamous metaplasia (males); - 24.4 mg/m^3^―3/10, very slight; 1/10, slight; 1/10, moderate; - 11.9 mg/m^3^―no lesions observed; - 1.2 mg/m^3^―no lesions observed; - 0 mg/m^3^―no lesions observed; - Very slight keratinization (males); - 24.4 mg/m^3^―2/10; - 11.9 mg/m^3^―no lesions observed; - 1.2 mg/m^3^―no lesions observed; - 0 mg/m^3^―no lesions observed; - Squamous metaplasia (females); - 24.4 mg/m^3^―no lesions observed; - 11.9 mg/m^3^―not examined; - 1.2 mg/m^3^―not examined; - 0 mg/m^3^―no lesions observed; - Very slight keratinization (females); - 24.4 mg/m^3^―no lesions observed; - 11.9 mg/m^3^―not examined; - 1.2 mg/m^3^―not examined; - 0 mg/m^3^―no lesions observed
Medium Confidence
Andersen et al. (2010); Fischer 344; male; 8/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers; 6 hours/day, 5 days/week for 1, 4, or 13 weeks. Rats sacrificed immediately after last exposure.; Test article: Paraformaldehyde.; Actual concentrations reported in the Results column. Target concentrations were 0, 0.8, 2.5, 7.4, 12.3, or 18.5 mg/m^3^.^a^; Histopathology: nasal sections at the nose tip and standard cross-section levels (I−V).; Main limitations: small N; data for levels III−V were not reported. | Target and Actual FA Concentrations
| | | | | | Actual concentration (mg/m^3^) for each exposure time
| Target | | | | | 1 week | | 4 weeks | | 13 weeks
| 0 | | | | | 0 ± 0 | | 0 ± 0 | | 0 ± 0
| 0.8 | | | | | 0.77 ± 0.06 | | 0.8 ± 0.09 | | 0.83 ± 0.07
| 2.5 | | | | | 2.5 ± 0.0 | | 2.5 ± 0.0 | | 2.5 ± 0.1
| 7.4 | | | | | 7.3 ± 0.2 | | 7.4 ± 0.2 | | 7.4 ± 0.2
| 12.3 | | | | | 12.2 ± 0.6 | | 12.3 ± 0.7 | | 12.3 ± 0.7
| 18.5 | | | | | 18.9 ± 0.1 | | 18.5 ± 0.6 | | 18.3 ± 0.5
| Incidence and severity of nasal squamous metaplasia^a^
| | | | | | FA (target concentrations)
| Region | | | | | 0 mg/m^3^ | 0.8 mg/m^3^ | 2.5 mg/m^3^ | 7.4 mg/m^3^ | 12.3 mg/m^3^ | 18.5 mg/m^3^
| Level I
| 1 week | | | | | 4^b^ (1)^c^ | 5 (1) | 8 (1.9) | 8 (1.6) | 8 (1.5) | 6 (1.2)
| 4 weeks | | | | | 1 (1) | 6 (1) | 7 (1) | 8 (1.5) | 8 (1.7) | 8 (2.2)
| 13 weeks | | | | | 1 (1) | 2 (1) | 8 (1.1) | 8 (1.8) | 8 (1.9) | 8 (2.4)
| Level II
| 1 week | | | | | 0 (NA) | 0 (NA) | 0 (NA) | 6 (1.1) | 8 (1.5) | 8 (1.5)
| 4 weeks | | | | | 0 (NA) | 0 (NA) | 0 (NA) | 5 (1) | 8 (1.2) | 8 (1.7)
| 13 weeks | | | | | 0 (NA) | 0 (NA) | 0 (NA) | 0 (NA) | 8 (2.9) | 8 (3.4)
| Data NR for levels III, IV, and V.; ^a^Squamous metaplasia diagnosed in areas with change in transitional or respiratory epithelium to squamous epithelium, with or without keratinization; ^b^8 animals examined at each time point and dose; ^c^Average severity score (1 = minimal, 2 = slight/mild, 3 = moderate, 4 = moderately severe).
| Incidence of nasal necrosis/erosion
| | | | FA (target concentrations)
| Region | | | 0 mg/m^3^ | | 7.4 mg/m^3^ | | 12.3 mg/m^3^ | | 18.5 mg/m^3^
| Level I
| 1 week | | | 0^a^ | | 6 | | 8 | | 8
| 4 weeks | | | 0 | | 3 | | 3 | | 6
| 13 weeks | | | 0 | | 0 | | 7 | | 4
| Level II
| 1 week | | | 0 | | 0 | | 7 | | 7
| 4 weeks | | | 0 | | 0 | | 5 | | 8
| 13 weeks | | | 0 | | 0 | | 0 | | 6
| Lesions ND at 0.8 and 2.5 mg/m^3^.; ^a^8 animals examined at each time point and dose.
Wilmer et al. (1989); Wistar rats; male; 25/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers either continuously for 8 hours/day, 5 days/week for 13 weeks or intermittently 8 hours/day (successive periods of 0.5 hour of exposure and 0.5 hour of nonexposure), 5 days/week for 13 weeks.; Test article: Paraformaldehyde.; Actual concentrations were not determined. Target concentrations were 0, 1.23, or 2.46 mg/m^3^ for continuous exposures and 0, 2.46, or 4.92 mg/m^3^ for intermittent exposures.^a^; Histopathology: 6 standard cross sections of the nose [note: same as Woutersen et al. (1989)]; Main limitations: analytical concentrations and lesion severities were not reported. | Histopathological changes in respiratory epithelium (cross section II) observed after 13 weeks of exposure
| | | | | | | Incidence of lesions
| | | | | | | A | B | C | D | E
| | | | | | | Control | 1.23 mg/m^3^ Contin. | 2.46 mg/m^3^ Contin. | 2.46 mg/m^3^ Inter. | 4.92 mg/m^3^ Inter.
| Disarrangement
| Focal | | | | | | 12/25 | 4/22 | 8/24 | 3/23^a^ | 8/25
| Diffuse | | | | | | 1/25 | 1/22 | 0/24 | 15/23^c^ | 11/25^b^
| Necrosis
| Focal | | | | | | 4/25 | 3/22 | 0/24 | 2/23 | 3/25
| Diffuse | | | | | | 0/25 | 0/22 | 0/24 | 2/23 | 2/25
| Basal cell hyperplasia
| Focal | | | | | | 9/25 | 4/22 | 6/24 | 11/23 | 10/25
| Diffuse | | | | | | 4/25 | 0/22 | 0/24 | 4/23 | 11/25
| Squamous metaplasia
| Focal | | | | | | 5/25 | 0/22 | 1/24 | 7/23 | 16/25^b^
| Keratinization | | | | | | 0/25 | 0/22 | 1/24 | 0/23 | 3/25
| Nest-like infolds
| Focal | | | | | | 5/25 | 4/22 | 11/24 | 14/23^b^ | 7/25
| Diffuse | | | | | | 0/25 | 3/22 | 1/24 | 0/23 | 1/25
| Goblet cell hyperplasia
| Focal | | | | | | 0/25 | 1/22 | 1/24 | 2/23 | 1/25
| Diffuse | | | | | | 5/25 | 2/22 | 8/24 | 13/23^a^ | 10/25
| Rhinitis | | | | | | 3/25 | 2/22 | 3/24 | 16/23^c^ | 8/25
| A = 0 mg/m^3^; B = 1.23 mg/m^3^ continuous (9.8 mg/m^3^ h/d); C = 2.46 mg/m^3^ continuous (19.7 mg/m^3^ h/d); D = 2.46 mg/m^3^ intermittent (9.8 mg/m^3^ h/d); E = 4.92 mg/m^3^ intermittent (19.7 mg/m^3^ h/d).; ^a^p < 0.05; ^b^p < 0.01; ^c^p < 0.001.
Zwart et al. (1988); Wistar rats; male and female; 50/group/sex.; Exposure: Rats were exposed to FA in dynamic whole-body chambers; 6 hours/day, 5 days/week for 13 weeks.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.37 (±0.02), 1.2 (±0.10), or 3.7 (±0.27) mg/m^3^.^a^; Histopathology: 6 standard cross sections of the nose [note: same as Woutersen et al. (1989)]; Main limitations: failed to completely report lesion incidence and lesion severities were not reported. | [Data only reported for cross sections II and III]; 3 days:; Nose:; - 3.7 mg/m^3^―Focal basal cell hyperplasia concomitant with loss of cilia observed at section III, number of rats and sex NR.; - Histological changes NR for other groups.; 13 weeks:; Nose:; - 3.7 mg/m^3^―Histological changes including epithelial disarrangement to epithelial hyperplasia and squamous metaplasia (with or without keratinization) found in 37/50 males and 21/50 females. Changes localized to the anterior part of section II that is normally covered by respiratory epithelium.; - Histological changes NR for other exposure groups at section II.; - No histological changes in respiratory epithelium observed in section III for any rat exposed to FA. Statistically significant differences in the incidences of inflammatory lesions (e.g., rhinitis, sinusitis, and aggregates of mononuclear cell infiltrates) in the pharyngeal ducts observed between control and treatment groups, although quantitative data NR and exposure-related response was absent.; - 3.7 mg/m^3^―Electron microscopic evaluation revealed: changes in nasal septa epithelium including loss of cilia, but not slender microvilli; strongly indented and disarranged epithelial cell nuclei; the presence of small blood vessels; interdigitations between epithelial cells and the presence of cilia in intracellular spaces; foci of keratinized squamous epithelium; and glandularization of goblet cells, which were arranged in gland-like structures.; - 0.37 and 1.2 mg/m^3^―Electron microscopic evaluation of section II showed no differences except for irregularly shaped and strongly indented nuclei when compared to controls.
Rusch et al. (1983); Fischer 344 rats; male and female; 20/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers for 22 hours/day, 7 days/week for 26 weeks.; Test article: Unstabilized 5% solution of formaldehyde (0.03% methanol).; Actual concentrations were 0.23 (±0.02), 1.2 (±0.1), or 3.6 (±0.22) mg/m^3^.^a^ Controls exposed to 0.011 (±0.009) mg/m^3^.; Histopathology: Four sections of lung, one section of trachea, and three transverse sections of nasal turbinates (anterior, middle, and posterior regions) and one transverse section of ethmoturbinate.; Main limitations: lesion severities were NR; data only reported for one section; metaplasia and hyperplasia reported together. | Microscopic evaluation of lungs and trachea for Groups I, III, V, and VI showed lesions frequently observed in laboratory animals but not considered exposure-related. Electron microscopic evaluation for Group I and II animals (5/sex) did not reveal turbinate, tracheal, or pulmonary ultrastructure changes associated with treatment.
| Observations in middle region of nasal turbinate
| Group | | | | | Exposure | | Squamous metaplasia and hyperplasia | | Basal cell hyperplasia
| I (control for II and III) | | | | | 0 mg/m^3^ | | 2/38 | | 0/38
| II | | | | | 0.23 mg/m^3^ | | 1/38 | | 0/38
| III | | | | | 1.2 mg/m^3^ | | 3/36 | | 0/36
| V (control for VI) | | | | | 0 mg/m^3^ | | 3/39 | | 4/39
| VI | | | | | 3.6 mg/m^3^ | | 23/37 | | 25/37
| For anterior nasal turbinates, no evidence of exposure-related effects with the possible exception for Group VI. When comparing to Group V, fourfold increase for the incidences of squamous metaplasia/hyperplasia and basal cell hyperplasia in Group VI; for posterior nasal turbinates, only Group VI showed evidence of squamous metaplasia (3/37); no evidence of exposure-related effects in ethmoturbinates; level of rhinitis comparable in Groups I, II, and III, but most frequent in Group VI.
Mice
Medium confidence
Maronpot et al. (1986); B6C3F1 mice; male and female; 10/sex/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers for 6 hours/day, 5 days/week for 13 weeks.; Test article: Formalin (9.2% w/v), assumed to contain methanol.; Actual concentrations were 2.41 (±0.25), 5.02 (±0.62), 12.4 (±0.80), 25.1 (±1.1), or 49.6 (±3.2) mg/m^3^.; Histopathology: sections of the nasal turbinates (3 sections), larynx, trachea, and lung.; Main limitations: formalin; small N | Lesions after 13 weeks of exposure:
| mg/m^3^: | 0 | | 5.02 | | 12.4 | | 25.1 | | 49.6
| Nasal cavity | M | F | M | F | M | F | M | F | M | F
| Metaplasia, squamous | 0/10 | 0/10 | 1/10 | 0/10 | 10/10 | 10/10 | 10/10 | 10/10 | 10/10 | 10/10
| Inflammation, seropurulent | 0/10 | 0/10 | 0/10 | 0/10 | 4/10 | 0/10 | 10/10 | 8/10 | 10/10 | 10/10
| No lesions observed after exposure to 2.41 mg/m^3^.
| mg/m^3^: | | | | | 0 | | 25.1 | | 49.6
| | | | | | M | F | M | F | M | F
| Larynx
| Metaplasia, squamous | | | | | 0/8 | 0/8 | 6/9 | 3/9 | 10/10 | 7/8
| Trachea
| Metaplasia, squamous | | | | | 0/10 | 0/9 | 3/10 | 5/10 | 10/10 | 10/10
| Hyperplasia, epithelial | | | | | 0/10 | 0/9 | 4/10 | 2/10 | 2/10 | 0/10
| Inflammation, purulent | | | | | 0/10 | 0/9 | 0/10 | 0/10 | 8/10 | 5/10
| Fibrosis, submucosal | | | | | 0/10 | 0/9 | 0/10 | 0/10 | 9/10 | 5/10
| Lung
| Bronchus, metaplasia squamous | | | | | 0/10 | 0/10 | 0/10 | 0/10 | 4/10 | 3/10
| Bronchus, inflammation | | | | | 0/10 | 0/10 | 0/10 | 0/10 | 3/10 | 2/10
| Bronchus, fibrosis, submucosal | | | | | 0/10 | 0/10 | 0/10 | 0/10 | 2/10 | 0/10
| No laryngeal lesions observed after 2.41, 5.02, or 12.4 mg/m^3^; no tracheal lesions observed after 2.41, 5.02, or 12.4 mg/m^3^, except 1/10 females (squamous metaplasia) after 12.4 mg/m^3^; no lung lesions after 12.4 mg/m^3^; data were NR for 2.41 and 5.02 mg/m^3^.
Hamsters
Medium confidence
Rusch et al. (1983); Syrian golden hamsters; male and female; 10/sex/group.; Exposure: Hamsters were exposed to FA in dynamic whole-body chambers for 22 hours/day, 7 days/week for 26 weeks.; Test article: Unstabilized 5% solution of formaldehyde (0.03% methanol).; Actual concentrations were 0.23 (±0.02), 1.2 (±0.1), or 3.6 (±0.22) mg/m^3^.^a^ Controls were exposed to 0.011 (±0.009) mg/m^3^.; Histopathology: 4 sections of lung, 1 section of trachea, and the hamster equivalent of the rat turbinate sections (i.e., 3 transverse sections of nasal turbinates [anterior, middle, and posterior regions] and one transverse section of ethmoturbinate).; Main limitations: lesion incidences NR (note: only metaplasia was investigated). | Microscopic evaluation of lungs and trachea for Groups I (controls for Groups II and III), III (1.2 mg/m^3^), V (controls for Group VI), and VI (3.6 mg/m^3^) showed lesions frequently observed in laboratory animals but not considered exposure related. Histopathological data for Group II (0.23 mg/m^3^) not reported.; No evidence of exposure-related effects for the incidence of squamous metaplasia even at 3.6 mg/m^3^ exposure level.
Monkeys
Medium confidence
Rusch et al. (1983); Cynomolgus monkeys; male; 6/group.; Exposure: Monkeys were exposed to FA in dynamic whole-body chambers for 22 hours/day, 7 days/week for 26 weeks.; Test article: Unstabilized 5% solution of formaldehyde (0.03% methanol).; Actual concentrations were 0.23 (±0.02), 1.2 (±0.1), or 3.6 (±0.22) mg/m^3^. Controls exposed to 0.011 (±0.009) mg/m^3^.^a^; Histopathology: 4 sections of lung, 1 section of trachea, and the monkey equivalent of the rat turbinate sections (i.e., 3 transverse sections of nasal turbinates [anterior, middle, and posterior regions] and one transverse section of ethmoturbinate).; Main limitations: lesion severities NR; incidence of squamous metaplasia and hyperplasia reported together; data reported for only one nasal section. | Microscopic evaluation of lungs and trachea for Groups I (controls for Groups II and III), III (1.2 mg/m^3^), V (controls for Group VI), and VI (3.6 mg/m^3^) showed lesions frequently observed in laboratory animals but not considered exposure related. Histopathological data for Group II (0.23 mg/m^3^) not reported.
| Observations in middle region of nasal turbinate
| Group | | | | | Exposure | | | Squamous metaplasia and hyperplasia
| I (control for II and III) | | | | | 0 mg/m^3^ | | | 0/6
| II | | | | | 0.23 mg/m^3^ | | | 0/6
| III | | | | | 1.2 mg/m^3^ | | | 1/6
| V (control for VI) | | | | | 0 mg/m^3^ | | | 0/6
| VI | | | | | 3.6 mg/m^3^ | | | 6/6
| For anterior and posterior nasal turbinates, no exposure-related effects reported.; Rhinitis observed in numerous animals from all Groups but with no apparent exposure-response.; For Group VI, observations of hoarseness, congestion, and nasal discharge were reported.

Organized by species, then confidence, then descending publication year. As discussed above, results from low confidence studies are not included given the many high and medium confidence studies (see Appendix B.3.5).

Abbreviations: FA = formaldehyde; NR = not reported, SD = standard deviation.

a Study authors originally reported FA concentrations in ppm. These values were converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

Table 3-28 Selected short-term respiratory pathology studies in animals (see Appendix C.6.1 for others)

Reference and study design | Results
Rats
Medium confidence
Kuper et al. (2011); Fischer rats; males; 8/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 day/week for 4 weeks.; Test article: Formalin (10.21% FA; although NR, the description supports the assumption that it was freshly prepared). Actual concentrations were 0, 0.63 (±0.06), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), and 18.4 (±0.06) mg/m^3^.^a^; Histopathology: 2 sections of nasopharynx-associated lymphoid tissues (NALT) and one section of an upper respiratory tract-draining lymph node (i.e., posterior, and superficial cervical lymph nodes).; Main limitations: small N; unclear test article | Incidence of lesions/changes after 4 weeks
| | FA (mg/m^3^)
| NALT | 0 | 0.63 | 1.23 | 2.48 | 7.53 | 12.3 | 18.4
| Size
| Very small | 1 | 0 | 0 | 1 | 0 | 2 | 1
| Small | 2 | 1 | 2 | 2 | 3 | 3 | 6
| Medium | 2 | 7 | 5 | 5 | 5 | 3 | 1
| Large | 3 | 0 | 1 | 0 | 0 | 0 | 0
| Decreased cellularity
| Slight | 0 | 0 | 0 | 0 | 0 | 0 | 1
| Moderate | 0 | 0 | 0 | 1 | 0 | 0 | 2
| Germinal center development
| Very slight | 1 | 5 | 3 | 3 | 3 | 3 | 0
| Moderate | 3 | 0 | 0 | 0 | 0 | 0 | 0
| Score expanded total | 4 | 5 | 3 | 3 | 3 | 3 | 0
| Epithelial hyperplasia
| Slight | 0 | 0 | 0 | 0 | 0 | 0 | 2
| Moderate | 0 | 0 | 0 | 0 | 0 | 0 | 5
| Score expanded total | 0 | 0 | 0 | 0 | 0 | 0 | 7^a^
| ^a^p < 0.01.
| Incidence of lesions/changes after 4 weeks
| | FA (mg/m^3^)
| | 0 | 0.63 | 1.23 | 2.48 | 7.53 | 12.3 | 18.4
| Posterior cervical lymph nodes
| Germinal center development
| Very slight | 3 | 3 | 2 | 4 | 4 | 5 | 5
| Slight | 0 | 1 | 2 | 1 | 2 | 0 | 0
| Moderate | 1 | 0 | 1 | 0 | 0 | 0 | 0
| Marked | 1 | 0 | 0 | 0 | 0 | 0 | 0
| Very marked | 0 | 1 | 0 | 0 | 0 | 1 | 1
| Score expanded totals | 5 | 5 | 5 | 5 | 6 | 6 | 6
| Superficial cervical lymph nodes
| Germinal center development
| Very slight | 5 | 3 | 2 | 0 | 3 | 1 | 0
| Very marked | 0 | 0 | 1 | 0 | 0 | 0 | 0
| Score expanded totals | 5 | 3 | 3 | 0a | 3 | 1 | 0^a^
| ^a^p < 0.05.
Wilmer et al. (1987); Wistar rats; male; 10/group.; Exposure: Rats were exposed to FA in a dynamic whole-body chamber either continuously for 8 hours/day, 5 days/week for 4 weeks or intermittently 8 hours/day (successive periods of 0.5 hour of exposure and 0.5 hour of nonexposure), 5 days/week for 4 weeks.; Test article: Paraformaldehyde.; Actual concentrations were not determined. Target concentrations were 0, 6.2, or 12.3 mg/m^3^ for continuous exposures and 0, 12.3, or 24.6 mg/m^3^ for intermittent exposures.^1^; Histopathology: 6 standard nasal cross sections.; Main limitations: analytical concentrations NR; lesion incidence and severities NR | Respiratory epithelium:; Focal thinning and disarrangement of mainly the lateral wall observed in all animals exposed to 24.6 mg/m^3^.; Squamous metaplasia and basal cell hyperplasia observed mainly in 12.3 and 24.6 mg/m^3^.; Rhinitis (minimal to moderate) observed in all groups.
| Severity of nasal lesions
| intermittent exposure to 24.6 mg/m^3^ (98.4 mg/m^3^-h/day) | | > | continuous exposure to 12.3 mg/m^3^ (98.4 mg/m^3^-h/day)
| intermittent exposure to 12.3 mg/m^3^ (49.2 mg/m^3^-h/day) | | > | continuous exposure to 6.2 mg/m^3^ (49.6 mg/m^3^-h/day)
| intermittent exposure to 12.3 mg/m^3^ (49.2 mg/m^3^-h/day) | | = | continuous exposure to 12.3 mg/m^3^ (98.4 mg/m^3^-h/day)
Mice
Medium confidence
Morgan et al. (2017); C3B6.129F1-Trp53^tm1Brd^ (C3B6 TP53±) and B6.129-Trp53^tm1Brd^ (B6 TP53±) mice; males; 24-35/group; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 day/week for 8 weeks.; Test article: Paraformaldehyde Nominal concentrations were 0, 9.23, or 18.45 mg/m^3^.^a^; Histopathology: 3 sections of the nasal cavity and one section of the larynx; Main limitations: somewhat limited sampling and minor reporting limitations; potentially short duration (however, lesions are observed) | Incidence (and severity) of noncancer nasal lesions at 32 weeks post-exposure
| | | FA (mg/m^3^)
| | | 0 | | 9.23 | | 18.45
| C3B6 TP53± mice
| Squamous Metaplasia (respiratory epithelium) | | 0/21 | | 14/21 (1.2) | | 22/23 (1.5)
| Hyperplasia (respiratory epithelium) | | 0/21 | | 0/21 | | 1/23 (1.0)
| Osteogenesis (turbinate) | | 0/21 | | 0/21 | | 3/23 (3.0)
| B6 TP53± mice
| Squamous Metaplasia (respiratory epithelium) | | 0/22 | | 13/27 (1.0) | | 17/26 (1.5)
| Osteogenesis (turbinate) | | 0/22 | | 1/27 (1.0) | | 1/26 (1.0)
| Average severity score based on 1= minimal; 2= mild; 3= moderate; 4= marked; No laryngeal lesions were reported
Kuper et al. (2011); B6C3F1 mice; females; 6/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 day/week for 4 weeks.; Test article: Formalin (10.21% FA; although NR, the description supports the assumption that it was freshly prepared).; Actual concentrations were 0, 0.63 (±0.06), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), and 18.4 (±0.06) mg/m^3^.^a^; Histopathology: 2 sections of nasopharynx-associated lymphoid tissues (NALT) and one section of an upper respiratory tract-draining lymph node (i.e., posterior and superficial cervical lymph nodes).; Main limitations: small N; unclear test article | Group | Observation
| Controls | NALT: varied in size from small to large; scarce germinal centers
| Exposed | Posterior and cervical lymph nodes: no FA-related changes NALT: no FA-related changes; no significant change in size compared to controls; scarce germinal centers
Monkeys
Medium confidence
Monticello et al. (1989); Rhesus monkeys; males; 3/group.; Exposure: Monkeys were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 days/week for 1 or 6 weeks.; Test article: Paraformaldehyde.; Actual concentrations were not determined. Target concentration was 0 or 7.4 mg/m^3^.^a^ Histopathology: 5 transverse sections of the nasal passages (A-E) extending from the nares to the soft palate. The evaluation also included cross sections of larynx and midtrachea, a frontal section of the carina, and sections of all lung lobes, which were trimmed mid-sagitally to include airway bifurcations.; Main limitations: analytical concentrations NR; lesion incidence and severities NR | Exposure | Observations (truncated from original article)
| Control | Nasal passages; Four types of epithelium identified:; (1) stratified squamous in the vestibule (Level A);; (2) transitional (Level A), present in narrow zone just posterior to vestibule;; (3) olfactory in mid-dorsal region (Levels B-D); and; (4) respiratory, the most extensive (Levels B-E) and present throughout remaining areas.; Extranasal respiratory tract; Typical pseudostratified columnar respiratory epithelium observed for the larynx, trachea, and major bronchi; mild inflammatory changes from pulmonary acariasis in one monkey
| 7.4 mg/m^3^ 1-week | Nasal passages; Characteristic changes in respiratory epithelium described as generally being bilaterally symmetrical and consistent in nature and severity for all three monkeys in group; Changes included loss of goblet cells and cilia, minimal-tomild epithelial hyperplasia with or without early stages of squamous metaplasia, and an accompanying neutrophilic inflammatory response; Squamous metaplasia present in various stages; metaplastic epithelium eroded (mild) in some areas; neutrophils occasionally found in metaplastic epithelium; maxillary sinuses exhibited no treatment-related lesions; Extranasal respiratory tract; Lesions of larynx, trachea, and carina were considered mild and included multifocal loss of cilia; extent of lesions covering surface area of larynx/trachea of 1-week group (3.0 ± 1.3%) was minimal compare to 6-week group (26.0 ± 10.0%); no treatment-related lesions in lungs
| 7.4 mg/m^3^ 6-week | Erosions absent; mild squamous metaplasia (more developed than in 1-week group); maxillary sinuses exhibited no treatment-related lesions; in two monkeys, olfactory epithelium exhibited small discrete areas of mild squamous metaplasia close to olfactory/respiratory epithelial interface; Extranasal respiratory tract; Lesions included multifocal areas of respiratory mucosa with loss of cilia and goblet cells, mild epithelial hyperplasia, and early squamous metaplasia with occasional squamous cell formation on the surface; no treatment-related lesions in lungs
| Exposure | Morphometric analysis of monkey nasal passages
| 7.4 mg/m^3^ 1-week | Anterio-posterior severity gradient for percentage of surface area with treatment-related lesions
| 7.4 mg/m^3^ 6-week | Of all nasal passage regions, middle turbinate had greatest percentage of surface area affected; Greater respiratory epithelium surface area with treatment-related lesions compared with 1-week group (p ≤ 0.05); More extensive lesions in the posterior nasal passages (Levels D−E) and larynx/trachea compared with same locations in 1-week group (p ≤ 0.05)
| 7.4 mg/m^3^ 1- and 6-week | Anterior regions (Levels B−C) had highest percentage of nasal mucosal surface area with treatment-related lesions

Organized by species, then confidence, then descending publication year. As discussed above, results from low confidence studies are not included given the many high and medium confidence studies (see Appendix B.3.5).

Abbreviations: FA = formaldehyde, NA = not applicable, ND = not detected, NR = not reported, SD = standard deviation, SE = standard error of the mean.

a Study authors originally reported FA concentrations in ppm. These values were converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

##### Summary of Animal Evidence Synthesis Judgments

The available animal studies on respiratory tract pathology provide robust evidence of formaldehyde exposure-induced effects. The evidence is clear and convincing across multiple factors, as summarized for the most influential factors below.

- Consistency and Study Confidence: Across numerous high and medium confidence studies formaldehyde exposure resulted in squamous metaplasia and hyperplasia in the respiratory epithelium. This effect was observed across animal species, from rodents to monkeys.
- Strength and Precision: Severe lesions were observed at higher formaldehyde concentrations, including observations of overt nasal tissue damage.
- Dose-Response: Multiple studies demonstrated a clear progression in lesion incidence, severity and anatomical location (moving deeper into the respiratory tract) with increasing formaldehyde exposure.
- Coherence: Multiple mechanistically related lesion types were observed following exposure.
- Biological Plausibility: Strong mechanistic evidence supports a progression of cellular and tissue-level changes that can lead to the development of the observed lesions.

In addition to the judgment above, several general inferences can be drawn based on the animal studies. Specifically, the animal data suggest that lesion development appears to be driven more by concentration than duration, particularly for the respiratory lesion of hyperplasia, and males may be more sensitive than females. In addition, studies of intentional damage to the nasal epithelium indicate that pre-existing nasal injury is likely to be a condition that would make individuals more susceptible to formaldehyde exposure-induced respiratory tract pathology.

#### Evidence on Mode of Action

Based primarily on studies in experimental animals or acutely exposed human volunteers (most of these endpoints are difficult to examine in long-term observational epidemiology studies), induction of histopathological lesions in the respiratory tract following formaldehyde exposure appears to result, at least in part, from a series of increasingly severe effects, including altered mucociliary function, damage to the nasal epithelium (e.g., sustained cytotoxicity), and sustained reparative cell proliferation culminating in a hyperplastic epithelium, or transitioning to an adaptive, metaplastic tissue (see Figure 3-17; see Appendix C.7 for additional details). Consistent with observations of metaplasia without hyperplasia in many of the rodent health effect studies, this pathway illustrates that metaplasia may develop following damage to the epithelium in the absence of hyperplasia (i.e., hyperplasia may not be an essential precursor). All the mechanistic events and relationships between events in the proposed pathway are based on robust or moderate evidence, indicating that this is likely a mechanism by which formaldehyde exposure causes squamous metaplasia. However, because modification of epithelial cell health and function in the URT can occur via multiple direct and indirect mechanisms following formaldehyde inhalation, which are expected to vary due to differences in both exposure duration and intensity, there are likely to be other plausible mechanisms by which formaldehyde exposure could cause this health effect. The current understanding provides strong biological support for an association between formaldehyde exposure and respiratory tract pathology. Additionally, as many of the mechanistic events in this pathway have been observed in both humans (sometimes indirectly) and experimental animals, including effects on mucociliary function and cell proliferation, as well as evidence of elevated oxidative stress, findings from experimental animals are considered relevant to humans.

Figure 3-17 Possible mechanistic associations between formaldehyde exposure and respiratory tract pathology

An evaluation of the formaldehyde exposure-specific mechanistic evidence informing the potential for formaldehyde exposure to cause respiratory health effects (see Table 3-29 and Appendix C.7) identified this sequence of mechanistic events as likely to be a mechanism by which formaldehyde inhalation could cause respiratory tract pathology, specifically squamous metaplasia, although it is assumed that other plausible pathways explaining this association have yet to be defined.

Some uncertainties remain regarding this pathway. Effects on the mucociliary system are likely secondary to the production of reactive byproducts in the URT or covalent modification to mucosal structural components following physical interactions of formaldehyde with proteins in the mucus, the latter of which at least would be expected to be driven largely by concentration. The nasal mucociliary apparatus cleans the airways by moving contaminant-laden mucus out of the URT. When damage to the cilia slows or disrupts the movement of the mucus, formaldehyde or other reactive molecules dissolved into the mucus may accumulate to a concentration that may be overtly toxic to the cells beneath the mucus. Thus, alterations to this normally protective apparatus could allow for greater access of inhaled formaldehyde (and other inhaled chemical and nonchemical substances) to epithelium lining the nasal passages (Harkema et al., 2006). Conversely, gradual tissue changes following exposure might also lead to resilience (e.g., increases in epithelial cell barrier function). Unfortunately, animal studies of mucociliary function and other detailed mechanistic studies characterizing the initial molecular interactions of formaldehyde in the URT following long-term exposure are unavailable. However, given the formaldehyde removal and metabolism processes in the nasal respiratory epithelium (see Appendix C.1), it would generally be expected that low levels of formaldehyde would be rapidly detoxified in healthy tissues, noting that changes in mucus flow patterns have been observed at lower formaldehyde levels than those eliciting URT epithelial lesions (i.e., at ≤0.3 mg/m^3^ in exposed humans and >0.6mg/m^3^ in animals).

Relatedly, while both hyperplasia and metaplasia, which generally represent attempts to protect the nasal epithelium from further insult, are often correlated with areas of cell proliferation (see Appendix C.7), similar evaluations were not identified for lesions such as necrosis. Although cell proliferation can occur in response to tissue damage, the concentrations at which cytotoxicity and tissue damage begin to occur are poorly defined compared to other respiratory tract lesions (i.e., hyperplasia; metaplasia), partly due to differences in methodology and reporting across studies. This complicates the interpretation of the potential progression (at least in terms of concentration) of these URT changes. Regardless, since increases in cell proliferation are largely adaptive responses to replace damaged and dying cells within the epithelial tissue layer, and proliferation is typically not observed below 1.23 mg/m^3^ (note: while proliferation is clearly increased above ~3.7 mg/m^3^, results across studies are mixed between 1.23 and 3.7 mg/m^3^; see Appendix C.7.1), cellular damage-induced proliferation at similar levels is assumed to represent an important mechanistic component for the development of URT pathology.

Interestingly, cellular proliferation “rates” (i.e., the available studies labeled dividing cells only during the last few days of exposures that varied in duration) did not appear to be strongly influenced by exposure duration (see Appendix C.7.1). Although differences exist, the general pattern of proliferation was similar across sets of studies exposing rats for either ≤1 week, 1−6 weeks, or ≥12 weeks. This similarity adds further support that cellular damage or pathology resulting in cell proliferation (i.e., hyperplasia) may not be highly dependent on exposure duration; it remains unclear whether the cumulative proliferative potential (i.e., proliferative events across the entire duration of exposure) might vary more strongly as a function of exposure duration, or to what extent this association might hold for lesions that may not be as dependent on proliferation (e.g., metaplasia). The broader implications of this relationship are discussed elsewhere (see Sections 3.2.5 and 5.2.1).

In addition, there are potential modifying factors that are not illustrated in Figure 3-17. One significant uncertainty relates to the potential for inflammatory and immunological changes in the upper airways (see Sections 3.2.2 and 3.2.3), which generally have been observed only after longer formaldehyde exposures, to modify the pattern or progression of mechanistic changes leading to the development of respiratory tract pathology. This understanding is further complicated because the available data are limited both in terms of understanding the specific initiating events leading to upper airway inflammatory changes, as well as their ability to clearly define the concentration and duration requirements for effects on URT immunological processes. As with the other examined health effects, uncertainties also exist regarding interindividual sensitivity to these effects, with respiratory health status and sensitivity to allergens expected to be strong modifiers of these effects. Nasal lesions are far more severe in rodents with prior nasal damage (e.g., (Woutersen et al., 1989; Appelman et al., 1988)), and similar observations have been made in exposed humans (Falk et al., 1994), while changes in mucus flow and related nasal features in allergic individuals would be expected to modify the more direct effects of formaldehyde on the mucociliary apparatus. Genetics may also play a role. For example, possibly complementing the hypothesized role of p53 in nasal genotoxicity (see Appendix C.3), two strains of p53 deficient mice (Trp53 heterozygotes) exhibited pronounced metaplasia after short-term (8-week) exposure (Morgan et al., 2017); however, this study did not include metaplasia rates in wild-type mice for comparison^23^ and there are no corresponding rat models, which would be presumed to be even more sensitive.

Overall, although uncertainties remain, the mechanistic evidence supports the conclusion that metaplasia and hyperplasia are likely to result, at least in part, from direct or indirect (e.g., through disruption of normal mucociliary function) effects on epithelial cell health, which often appears to involve sustained cellular proliferation, particularly for hyperplasia.

Table 3-29 Mechanistic evidence most informative to the development of respiratory tract pathology after formaldehyde inhalation

Endpoint | Study-specific findings and confidence | | Summary of evidence | Conclusion
The majority of these mechanistic changes have been discussed in previous sections.; See Table 1-3 for presentation of the evidence for: ↑ URT oxidative stress (moderate); See Table 1-10 for presentation of the evidence for: URT protein/DNA modification (robust); URT mucociliary dysfunction (robust); and URT epithelial damage (robust)
↑ URT Cellular (epithelial) Proliferation; (see Appendix C.7 for additional detail and discussion) | High or Medium | Human: None (note: indirect data from human studies indicating an increase in histopathological scores that included hyperplasia were not specific enough to independently evaluate proliferation). | Increased cell proliferation in rats at all tested durations. Proliferation increases were typically observed in the anterior nasal cavity at tested levels ≥^~^3.5–4 mg/m^3^, and were generally not observed at ≤1.23 mg/m^3^. Sites of proliferation correlated with the development of hyperplasia and metaplasia, although the temporal and exposure levels specifics of this association are unclear. Indirect data from observations of hyperplasia in exposed animals and humans are consistent with these data. | Robust
↑ URT Cellular (epithelial) Proliferation; (see Appendix C.7 for additional detail and discussion) | High or Medium | Animal: Acute dose-dependent increases in cell proliferation in rats, measured primarily by DNA labeling during the final days of exposure, were consistently observed following acute, shortterm, and subchronic exposure, and generally with a similar magnitude of responses across durations. Proliferation was typically highest in anterior regions (e.g., “level 2”), with little evidence of proliferation at ≤1.23 mg/m^3^, mixed findings between 1.24 and 3.5 mg/m^3^, and studies generally reporting increases with exposure at higher levels, particularly with longer exposure duration. These data are supported by consistent observations of formaldehyde exposure-induced increases in hyperplasia in pathology studies, some of which provided information showing a correlation between acute proliferation and hyperplasia and metaplasia. The only rat study that measured exposure longer than 13 weeks suggests that increases in acute proliferation may begin to decrease in magnitude with chronic exposure at ≥6 mg/m^3^ (Monticello et al., 1996). A few studies suggest that mice may exhibit less robust responses than rats, while monkeys may exhibit proliferation in more posterior nasal regions at >7 mg/m^3^. | | Robust
↑ URT Cellular (epithelial) Proliferation; (see Appendix C.7 for additional detail and discussion) | Low | N/A: Sufficient information for ‘robust’ from high or medium confidence studies.

##### Summary of Inferences Regarding Mode of Action

Robust or moderate evidence for mechanistic events based predominantly on experimental animal studies supports a biological progression of changes that appears to include mucociliary dysfunction, epithelial damage, and often cellular proliferation, leading to the eventual development of nasal lesions, including squamous metaplasia. Thus, although it may be incomplete, a MOA involving effects on mucociliary function and epithelial cell health is well supported and considered to be a major contributor to these effects.

#### Evidence Integration Summary

The literature on formaldehyde effects on respiratory tract pathology in animals provides robust evidence that inhaled formaldehyde exposure can induce histopathologic lesions in the URT of animals, primarily in the nasal cavity, in a manner dependent on both the concentration and, to a lesser extent (particularly for hyperplasia), duration of exposure. Based on numerous high and medium confidence studies of chronic and subchronic exposure duration, formaldehyde exposure resulted in lesions in the respiratory epithelium, including goblet and basal epithelial cell hyperplasia, necrosis, and squamous metaplasia (see Tables 3-26 and 3-27). These lesions have been observed across experimental animal species, including monkeys, mice, and hamsters, but primarily in rats. In general, rats appear to be more sensitive than mice or hamsters, while the limited data in monkeys suggest a similar sensitivity to rats with possible differences in lesion location. While these lesions consistently develop in rodents of both sexes, several studies suggest an increased susceptibility of males as compared to females, potentially due to differences in breathing patterns. Presumably due to the high reactivity and water solubility of formaldehyde, these pathological lesions have been primarily assessed (and subsequently observed) in the epithelium lining the anterior regions of the rodent nasal passages following formaldehyde inhalation exposure, mostly in regions containing respiratory epithelium. Generally, at higher concentrations or longer durations, similar effects are seen in more posterior sections of the nasal cavity (and sometimes beyond), as well as in the olfactory epithelium. Additionally, lesions progress in severity (e.g., slight to moderate) at specific anatomical locations (e.g., cross-section level) with increasing concentration or duration of exposure, indicating cumulative effects. While several studies support that an increased incidence of nasal lesions such as hyperplasia and metaplasia persists after cessation of exposure, partial regression (e.g., a reduced severity or smaller increase in incidence) of these lesions appears to occur, at least in mice and rats.

Although the evidence is more equivocal in one study (Boysen et al., 1990), the four human epidemiology studies examining histopathology found that participants exposed to average formaldehyde levels between 0.05 and 0.6 mg/m^3^ had a higher average histopathology score than their respective comparison group (Holmstrom et al., 1989c; Edling et al., 1988; Ballarin et al., 1992). Although the studies were limited by probable survival bias, and in some cases other limitations that resulted in a bias toward the null, a consistent association with histopathological endpoints, including squamous metaplasia, was observed. Therefore, the observational human data provide moderate evidence that inhaled formaldehyde induces histopathological lesions in the URT.

Mechanistic insights based on a large amount of animal data (some similar effects were observed in humans, although the data were sparse) indicate a likely role for altered mucociliary function or cellular proliferation in the occurrence of these exposure-induced lesions (see Appendix C.7). Overall, the strength of the evidence for hyperplasia and squamous metaplasia includes robust evidence from animal studies and moderate human evidence from observational epidemiology studies, and strong support for a plausible MOA based largely on mechanistic evidence in animals (supported by more limited, coherent findings in human mechanistic studies), Therefore, the evidence demonstrates that inhalation of formaldehyde causes respiratory tract pathology in humans given the sufficient exposure conditions. The primary basis for this conclusion is rat bioassays of chronic exposure that consistently observed squamous metaplasia at formaldehyde exposure levels ≥2.5 mg/m^3^.

Table 3-30 Evidence integration summary for effects of formaldehyde inhalation on respiratory pathology

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Respiratory Pathology
Human | Consistency and Study Confidence | - Three of the four medium confidence occupational studies observed a higher prevalence of abnormal nasal histopathology, including loss of ciliated cells, hyperplasia, and squamous metaplasia at concentrations ranging from 0.1–2 mg/m^3^; the remaining (1) study had more equivocal findings. | | Moderate; Based on consistent observations of abnormal histopathology, including squamous metaplasia in exposed workers. | The evidence demonstrates that inhalation of formaldehyde causes respiratory tract pathology in humans, given sufficient exposure conditions^a^; This judgment is primarily based on rat bioassays of chronic exposure which consistently observed squamous metaplasia at formaldehyde exposure levels ≥2.5 mg/m^3^.; Potential Susceptibilities: Variation in sensitivity may depend on differences in URT immunity, allergen sensitivity, and nasal structure or past injury (e.g., studies support increased sensitivity of rodents with intentionally damaged nasal cavities), and males may be more sensitive than females.
Human | Strength and Precision | N/A | | Moderate; Based on consistent observations of abnormal histopathology, including squamous metaplasia in exposed workers.
Human | Dose-Response | N/A | | Moderate; Based on consistent observations of abnormal histopathology, including squamous metaplasia in exposed workers.
Human | Coherence | N/A | | Moderate; Based on consistent observations of abnormal histopathology, including squamous metaplasia in exposed workers.
Human | Biological Plausibility | - Mechanistic changes in one medium confidence and one low confidence study in humans provides evidence of changes in mucociliary clearance and mucus flow beginning at formaldehyde concentrations of 0.25–0.3 mg/m^3^. This provides some minimal additional support for biological plausibility. | | Moderate; Based on consistent observations of abnormal histopathology, including squamous metaplasia in exposed workers.
Animal | Consistency and Study Confidence | - Consistent evidence of squamous metaplasia and hyperplasia in the nasal respiratory epithelium across numerous independent high and medium confidence studies.; - Consistent evidence of both metaplasia and hyperplasia in monkeys, rats, mice, and hamsters; the data were more limited for monkeys, while mice and hamsters exhibited less sensitivity. | | Robust; Based on consistent, dose-dependent, and coherent evidence of pathological changes in numerous studies across multiple species, with strong support for biological plausibility. Generally, the most sensitive effects were metaplasia observed after chronic exposure to ≥2.5 mg/m^3^ formaldehyde.
Animal | Strength and Precision | - At higher concentrations, lesions were more severe, including some with evidence of overt nasal tissue damage.
Animal | Dose-Response | - Multiple studies provided clear evidence of a concentration dependence for lesion development, as demonstrated by increases in the incidence, severity, and anatomical location of the observed lesions with increasing exposure.
Animal | Coherence | - Multiple mechanistically related lesion types were consistently observed.
Animal | Biological Plausibility | - Robust or moderate evidence for mechanistic events based predominantly on experimental animal studies supports a biological progression of changes that appears to include mucociliary dysfunction, epithelial damage, and often cellular proliferation, leading to the eventual development of nasal lesions, including squamous metaplasia.
Other inferences | - Relevance to humans: Similarities in the function and properties of the nasal epithelium across species, as well as similar mechanistic and apical effects observed in both humans and animals, provide strong support for the relevance of the findings in animals to humans.; - MOA: Although it may be incomplete, a MOA involving effects on mucociliary function and epithelial cell health is well supported and considered to be a major contributor to these effects.; - Other: Data from animal studies suggest that lesion development may be driven more by concentration than duration, particularly for hyperplasia. While estimates for formaldehyde were not identified, estimates for other irritants indicate that concentration is ^~^1.8- to 1.9-fold (on average) more influential than duration regarding exposure-induced mortality after acute exposure.

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

### 3.2.5 Respiratory Tract Cancers

This section examines the evidence pertaining to the carcinogenic effect of formaldehyde exposure on the upper respiratory tract (URT) of humans and animals. The specific endpoints considered in this section include diagnoses of nasopharyngeal cancer, sinonasal cancer, cancers of the oropharynx and hypopharynx, and laryngeal cancer in exposed humans; experimental animal studies examining the potential for cancers of the nasal cavity and proximal regions of the URT (note: the results of several studies that also included examinations of more distal regions of the respiratory tract are discussed); and mechanistic studies relevant to interpreting potential carcinogenic effects on the URT. In humans, URT cancers were reviewed independently of one another based on primary data from case-control and cohort studies (the approximate structural delineations referred to in the section on human evidence are shown below in Figure 3-18).

Epidemiological findings provide robust evidence for nasopharyngeal cancers (NPCs), and sinonasal cancer, based on groups with occupational exposure. Epidemiological evidence is slight for oropharyngeal/hypopharyngeal cancers, and indeterminate for laryngeal cancers, respectively. Evidence for a carcinogenic effect in the URT of humans is further supported by experimental animal studies. Precancerous lesions (e.g., dysplasia) and tumors (primarily squamous cell carcinomas) were observed in the nasal cavities of multiple species/strains of rodents. Such observations in animals were concentration and duration dependent. Mechanistic data suggest that URT cancers are likely the result of genotoxicity and mutagenicity, cytotoxicity, and cell proliferation. Together, genotoxicity, cellular proliferation, and cytotoxicity-induced regenerative proliferation exhibit multiple layers of coherence as a function of species, anatomy, temporality, concentration, and duration of exposure, and when these factors are integrated, they form a biologically relevant MOA for formaldehyde-induced URT carcinogenesis.

The evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer (NPC) in humans, based on robust epidemiological evidence of an increased risk of the occurrence of NPCs from studies of occupational formaldehyde exposure in several geographic locations among different occupational populations representing diverse exposure settings; robust evidence from long-term bioassays in two animal species providing consistent and reliable evidence of nasal cancers following exposure; and reliable and consistent mechanistic evidence in both animals and humans supporting causality. The nasopharynx, although not typically specified in animal studies, is the region adjacent to the nasal cavity, where the animal evidence was predominantly observed, providing plausible coherence between the animal and human data (and thus, the animal evidence is reflected as robust for the purpose of interpreting human NPC). The evidence is sufficient to conclude that a mutagenic mode of action of formaldehyde is operative in formaldehyde-induced nasopharyngeal carcinogenicity.

The evidence demonstrates that formaldehyde inhalation causes sinonasal cancer (SNC) in humans, based on robust epidemiological evidence of an increased risk of the occurrence of sinonasal cancer from studies of occupational formaldehyde exposure in several geographic locations among different occupational populations representing diverse exposure settings. This evidence is supported by the apical and mechanistic evidence for nasal cancers across multiple animal species, although some uncertainty remains in the interpretation of the animal nasal data as wholly applicable to interpreting sinonasal cancer (and thus, the animal evidence is reflected as moderate for the purpose of interpreting human SNC). Despite some uncertainty in the applicability of the animal data to human SNC, the identified nasal cancer MOA, including mutagenicity, is interpreted as relevant to this cancer type.

Figure 3-18 Schematic diagram of the human upper respiratory tract (i.e., nose, nasal cavity, paranasal sinuses, pharynx, larynx), as well as neighboring structures (from Vokes et al. (1993))

#### Upper Respiratory Tract Cancers in Human Studies

Each specific type of upper respiratory tract (URT) cancer (nasopharyngeal cancer, sinonasal cancer, cancers of the oropharynx and hypopharynx, and laryngeal cancer) is reviewed and evaluated independently in the sections below. For each type of URT cancer, the evidence is organized by considerations that inform the strength of evidence (e.g., consistency, exposure-response) and evaluation of the potential for bias and insensitivity in individual studies to affect the estimates of relative risk. Evidence tables for each type of URT cancer (Tables 3-32 through 3-35) are included and are organized first by the study evaluation conclusions (i.e., high, medium, low) and then by publication year.

##### Nasopharyngeal cancer

###### Epidemiological evidence

The most specific classification of nasopharyngeal cancer diagnosis that is commonly reported on death certificates across the epidemiological literature has been based on the first three digits of the Seventh (i.e., nasopharyngeal cancer ICD-7: 146), Eighth, or Ninth Revision of the ICD code (i.e., nasopharyngeal cancer ICD-8/9: 147) although some studies did report the histological type of cancer (i.e., squamous cell carcinoma and nonkeratinizing or undifferentiated cancer), the histological type is infrequently reported on death certificates.

Evidence describing the association between formaldehyde exposure and the risk of developing or dying from nasopharyngeal cancer is available from 20 epidemiological studies—12 case-control studies (Yu et al., 2004; Yang et al., 2005; West et al., 1993; Vaughan et al., 1986a, b; Vaughan, 1989; Vaughan et al., 2000; Roush et al., 1987b; Olsen et al., 1984; Li et al., 2006; Hildesheim et al., 2001; Armstrong et al., 2000) and eight cohort studies (Siew et al., 2012; Meyers et al., 2013; Malker et al., 1990; Hauptmann et al., 2009; Hansen and Olsen, 1995; Dell and Teta, 1995; Coggon et al., 2014; Beane Freeman et al., 2013). These are the only primary studies that provide evidence of the effect of formaldehyde exposure on the risk of dying from nasopharyngeal cancer. The outcome-specific evaluations of confidence in the precise effect estimate of an association from each study are provided in Appendix B.3.9. Note that the confidence judgments are for the confidence in the precise effect estimate of an association from each study—and not a confidence judgment in the overall study. The distinction here is important in that a study of adequate quality overall may still report an effect estimate judged to be of low confidence due to the rarity of the cancer outcome, the rarity of the exposure, or noncritical biases that are expected to yield effect estimates that underestimate any true effect. The results from Li et al. (2006) were classified as not informative due to the rarity of exposure in both the case and control groups; for details see Appendix B.3.9. The reported result from a case-control study by Armstrong et al. (2000) was classified as not informative due, primarily, to the rarity of relevant exposure data as only 8/564 subjects (1.4%) had more than 10 years of potential exposure beyond a 10-year latency period, and thus the study lacked sensitivity to detect any true effect (see Appendix B.3.9). The results from Dell et al. (1995) were classified as not informative due to the rarity of exposure in the cohort with 111 men exposed to formaldehyde out of 5932 (1.9%) and there were no observed cases of nasopharyngeal cancer; for details see Appendix B.3.9. Details of the reported results of high, medium, and low confidence are provided in the evidence table for nasopharyngeal cancer (see Table 3-32) following the causal evaluation.

###### Consistency of the observed association

Seventeen informative studies reported risks of nasopharyngeal cancer among subjects with formaldehyde exposure based on occupational or residential history. These studies examined different populations, in different geographical locations, under different exposure settings and employing different study designs. Importantly, for nasopharyngeal cancer, these studies were conducted in low background risk populations (e.g., Europe and the United States) and high background risk populations (e.g., China and Taiwan). Table 3-31 provides the incidence rates of nasopharyngeal cancer per year by country/region based on the IARC publication Cancer Incidence in Five Continents (Curado et al., 2007) for each of the 17 studies.

Table 3-31 Age-standardized (world) incidence rates of nasopharyngeal cancer per 100,000 people per year

Study | Country | Region | Incidence rate/year (per 100,000)
Siew et al. (2012) | Finland | | 0.3
Coggon et al. (2014) | England and Wales | South and Western | 0.4
Hansen and Olsen (1995) | Denmark | | 0.4
Malker et al. (1990) | Sweden | | 0.4
Olsen et al. (1984) | Denmark | | 0.4
Vaughan et al. (2000) | United States | CT, Detroit, IA, Seattle, UT | 0.4–0.7
Meyers et al. (2013) | United States | Georgia and Pennsylvania | 0.5–0.6
Beane Freeman et al. (2013) | United States | National Cancer Registries | 0.6
Hauptmann et al. (2009) | United States | National Cancer Registries | 0.6
Vaughan (1989) | United States | Washington | 0.6
Roush et al. (1987a) | United States | Connecticut | 0.6
Vaughan et al. (1986a) | United States | Washington | 0.6
Vaughan et al. (1986b) | United States | Washington | 0.6
Yang et al. (2005) | Taiwan^a^ | | 3.5–8.3
Hildesheim et al. (2001) | Taiwan^a^ | | 3.5–8.3
West et al. (1993) | Philippines | | 5.8
Yu et al. (2004) | China | Hong Kong | 17.8

a Taiwan is not included in the IARC publication of cancer incidence rate so data were obtained from Chen et al. (2002).

Also important for nasopharyngeal cancer is the consideration of histological subtype, which may be of a keratinizing or nonkeratinizing cell type as the proportion of each cell type varies in low and high-risk populations. The study results presented in Table 3-32 (by confidence level and publication date) detail all of the reported associations. Results are plotted in Figure 3-19; results are grouped by population background risk and arrayed from lowest to highest by the percentage of cases in each study’s results, which were considered likely to be squamous cell carcinomas.

Fourteen out of 17 studies reported increased risks of nasopharyngeal cancer with at least one metric of formaldehyde exposure—often with both clear statistical significance and exposure-response relationships. These included the results of large cohort study of 25,619 U.S. workers (Beane Freeman et al., 2013) classified with high confidence, and all four sets of results classified with medium confidence (see Table 3-32). Nine studies in eight independent populations reported relative effect estimates greater than three-fold. Yang et al. (2005) reported an OR of 4.29 (95% CI 2.45, 7.51) among cases with the highest cumulative formaldehyde exposure; Yu et al. (2004) reported a mortality odds ratio (MOR) of 3.75 (95% CI 1.12, 12.54) for restaurant workers in Hong Kong; West et al. (1993) reported an OR = 4.0 (95% CI 1.3,12.3) among Philippine cases with greater than 25 years of time since first exposure (TSFE); Roush et al. (1987a) reported an OR = 4.0 (95% CI 1.3, 12.0) among Connecticut cases aged 68+ years with the highest duration of exposure and 20+ years TSFE; Beane Freeman et al. (2013) reported an RR = 11.54 (95% CI 1.38, 96.81) for workers with the highest average intensity of exposure; Malker et al. (1990) reported a standardized incidence ratio (SIR) of 3.9 (95% CI 1.24, 9.40) among workers employed in fiberboard plants; Vaughan et al. (1986b) reported an OR = 6.7 (95% CI 1.2, 38.9) for cases living and working in a mobile home; Vaughan (1989) reported an OR = 31.8 (no CI provided) for the highest duration of working as a carpenter; and Vaughan et al. (2000), after excluding undifferentiated and nonkeratinizing histological types, reported an OR = 13.3 (95% CI 2.5, 70) for cases with the highest likelihood of formaldehyde exposure.

Results showing increased risks were consistently reported in populations from high-risk areas with endemic Epstein-Barr infection such as Hong Kong (Yu et al., 2004), Taiwan (Yang et al., 2005; Hildesheim et al., 2001), the Philippines (West et al., 1993) as well as in populations from low/medium-risk areas such as the United States (Vaughan et al., 1986a, b; Vaughan, 1989; Vaughan et al., 2000; Roush et al., 1987a; Beane Freeman et al., 2013). Results showing increased risks were also consistently reported across study populations with different proportions of squamous cell carcinomas (SCC) (i.e., Hildesheim et al. (2001) and Yang et al. (2005) reported only 9% of their cases were keratinizing SCC), more heterogeneous mixes of keratinizing and nonkeratinizing carcinomas [i.e., Malker et al. (1990), (48% keratinizing SCC); Vaughan et al. (2000), (60%); (Vaughan et al., 1986a, b), (78%)], and study populations restricted to only squamous cell carcinomas (Vaughan, 1989; Vaughan et al., 2000) (100% keratinizing SCC)].

Of these 17 studies, all but three reported increased risks of nasopharyngeal cancer that appeared to be associated with exposure to formaldehyde; the three exceptions were the results from the large occupational cohort studies by Siew et al. (2012), Coggon et al. (2014), and Meyers et al. (2013)—all of which were classified with low confidence. One additional study (Andjelkovich et al., 1995) reported zero cases of NPC among 3,929 U.S. workers exposed to formaldehyde over 83,064 person-years but reported no data on the number of expected cases and thus was not included here.^24^ An additional study (Edling et al., 1987b) reported one case of NPC among 521 Swedish workers exposed to formaldehyde over 7,011 person-years but reported no data on the number of expected cases and was not included here.^25^ One possible explanation for the inconsistency is the rarity of NPC in the populations studied by Siew and by Coggon. Table 3-32 shows that the Finnish population studies by Siew et al. (2012) had a background incidence rate of 0.3 cases per year for each 100,000 people—the lowest of all the available populations reviewed here. The English and Welch population studied by Coggon et al. (2014) had the second lowest incidence rate at 0.4 cases per year for each 100,000 people.^26^ The very low national incidence rates of NPC can make studies of these populations lack the statistical sensitivity to detect any true association—even when the number of people being followed appears to be large.

It is important to understand that the statistical power of these cohort studies depends directly on the number of observed and expected cases. While there are exact methods to compute the variance of the standardized mortality ratio, the general formula illustrates the dependence on the case counts. The variance of the standardized mortality ratio is generally a function of the inverse of the observed and expected case count, specifically, var(SMR) = [# observed cases/(# of expected cases)^2^]. Smaller case counts produce larger statistical variances and wider confidence intervals. Because the SMR is a measure of relative effect bounded between zero and infinity, it may be more straightforward to consider the width of confidence intervals on the scale of the natural logarithm, which bounds the estimates symmetrically between negative infinity and positive infinity. Coggon et al. (2014) expected only 1.7 deaths from nasopharyngeal cancer in the exposed workers and observed just one resulting in an unstable estimated RR = 0.38 (95% CI 0.02, 1.90); on the natural log scale the ln(RR) = −0.97 (95% CI −3.91, to 0.64). Meyers et al. (2013) expected only 1.33 deaths and did not observe any deaths, resulting in an SMR = 0 (95% CI 0, 2.77); on the natural log scale, the ln(RR) = negative infinity (95% CI negative infinity to +1.99). These effect estimates result in wide confidence intervals. For comparison, the other large cohort study (Beane Freeman et al., 2013) expected 4.89 deaths and observed nine deaths from NPC, resulting in a SMR = 1.84 (95% CI 0.84, 3.49); on the natural log scale, the ln(RR) = negative infinity (95% CI −0.17, 1.25). The NPC results from the Coggon et al. (2014), Meyers et al. (2013) and Siew et al. (2012) studies were all considered to lack sensitivity to detect any true effect, which contributed to their classifications of low confidence.

In summary, the majority of studies from different populations, in different locations, exposure settings, and using different study designs reported increased risks of nasopharyngeal cancer associated with formaldehyde exposure. There are reasonable alternative explanations for the three studies that did not observe an increased risk.

###### Strength of the observed association

While reported relative effect estimates were consistently elevated above the null value of one across 14 of the 17 studies, the magnitude of the relative risk estimates varied with the quality of the exposure assessment. Studies with higher quality exposure data that were capable of stratifying subjects by exposure level, exposure probability, and timing of exposure (including lagged exposures) generally reported higher relative effect estimates. Nine studies reported greater than three-fold increased risks of nasopharyngeal cancer that appeared to be associated with exposure to formaldehyde (Yu et al., 2004; Yang et al., 2005; West et al., 1993; Vaughan et al., 1986b; Vaughan, 1989; Vaughan et al., 2000; Roush et al., 1987a; Malker et al., 1990; Beane Freeman et al., 2013). Three studies reported greater than 10-fold increased risks of nasopharyngeal cancer in the highest exposure categories. These increased risks appeared to be associated with duration of exposure to formaldehyde after accounting for a latency period (Vaughan, 1989; Vaughan et al., 2000; Beane Freeman et al., 2013). Results from the studies with higher quality exposure data were judged with greater confidence.

###### Temporal relationship of the observed association

Two related aspects of time are encompassed in the consideration of temporality. One aspect is the necessity for the exposure to precede the onset of the disease. In each of the studies, the formaldehyde exposures among the study participants started before their diagnoses of NPC, and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and done in a blinded fashion with respect to outcome status.

The second aspect involves the time course of formaldehyde exposures in relation to the incidence of NPC and death from NPC. From the epidemiological literature, it is known that there can be an induction/latency period for some environmental agents and that the induction period may exceed 10 years. Three studies provided analyses of this temporal relationship showing some evidence of the effect of time since first exposure on the risk of dying from nasopharyngeal cancer (West et al., 1993; Roush et al., 1987b; Hildesheim et al., 2001); however, none of them did so by histological subtype. Hildesheim et al. (2001) reported conflicting evidence of lower risks among all NPC cases for first exposure to formaldehyde more than 20 years earlier, but higher risks with greater time since first exposure (TSFE) when analyses were limited to only those who were positive for Epstein-Barr virus. Roush et al. (1987b) reported somewhat greater risks among those first exposed more than 20 years and a stronger such pattern among those considered to be highly exposed more than 20 years prior to dying of nasopharyngeal cancer. Even higher risks were found among those with high early exposures and who were 68 years or older at death (OR = 4.0; 95% CI 1.3, 12.0), which may imply that TSFE much greater than 20 years carries greater risk. The results from West et al. (1993) support this assertion; in multivariate analyses, they reported a low odds ratio for TSFE less than 25 years but higher risks for greater than 25 years (OR = 4.0; 95% CI 1.3, 12.3). In separate analyses controlling only for TSFE to formaldehyde, dust, and exhaust fumes, West et al. (1993) reported even higher risk among those first exposed to formaldehyde more than 35 years earlier (OR = 5.6; 95% CI 0.58, 52.9).

The histological subtype and background rate of nasopharyngeal cancer is important in considering latency as the population studied by Hildesheim et al. (2001) resided in Taiwan (a high background risk population), and cases were more than 90% nonkeratinizing. In contrast, the population Roush et al. (1987b) studied was from Connecticut (a low background risk population), which may have only ~28% nonkeratinizing cases, if consistent with a U.S. study of nasopharyngeal cancer that included cases from Connecticut (Vaughan, 1989). West et al. (1993) studied subjects from the Philippines where the background rate is intermediate to the high rates of some East Asians and the low rates in populations of European descent (Hildesheim et al., 1993).

The association between exposure to formaldehyde and risk of nasopharyngeal cancer may be weaker for nonkeratinizing cases (Vaughan et al., 2000). This may explain the apparent lack of a clear latency effect in the Hildesheim et al. (2001) study, which has more than 90% of cases diagnosed with nonkeratinizing cases. The remaining limited evidence on the time course of death following initial formaldehyde exposure is consistent with expectation of a lengthy latency period for cancer development and subsequent deaths.

###### Exposure-response relationship

In their large population-based case-control study including 196 cases of nasopharyngeal cancer, Vaughan et al. (2000) clearly demonstrated two important points: (1) that there was an exposure-response relationship between increased formaldehyde exposure and increased risk of nasopharyngeal cancer, and (2) that the exposure-response differed by nasopharyngeal cancer subtype in the U.S. population. Vaughan et al. (2000) reported statistically significant trends for differentiated squamous cell carcinomas (p = 0.033) and for cases of epithelial carcinoma without specification of histological type (p = 0.036). However, there was no trend with duration of exposure to formaldehyde among cases with undifferentiated/nonkeratinizing histology (p = 0.82). Grouping of all histological subtypes appeared to mask the underlying relationship seen in squamous cell carcinoma in this study. Excluding nasopharyngeal cancer cases with undifferentiated or nonkeratinizing histology, Vaughan et al. (2000) reported a clear exposure-response with increased probability of exposure to formaldehyde with the highest risks seen in subjects with the highest probability of occupational exposure to formaldehyde (OR = 13.3; 95% CI 2.5, 70; p = 0.0007). Among those subjects considered to be “definitely exposed,” there were increasing risks of nasopharyngeal cancer with increasing duration of formaldehyde exposure (p < 0.001) and with increased cumulative formaldehyde exposure (p < 0.001).

Further evidence of exposure-response relationships was reported by Beane Freeman et al. (2013) for peak formaldehyde exposures (p = 0.005), and, to a lesser degree, for cumulative exposures (p = 0.06) and with average intensity of formaldehyde exposure (p = 0.09)^27^. Other supporting evidence of an exposure-response relationship between increased exposure to formaldehyde and increased risk of NPC come from three reports on the same study population in Washington state (Vaughan et al., 1986a, b; Vaughan, 1989). These studies reported higher risks with increasing occupational exposures but did not report tests of trend (Vaughan et al., 1986a); for example, with a 15-year lag, compared to the lowest exposure score, those in the second level had an OR = 1.7 (95% CI 0.5, 5.7), while those in the third level had an OR = 2.1 (95% CI 0.4, 10.0). These researchers also reported increased risks with length of residence in mobile homes with the risk peaking among those with more than 10 years of occupancy (OR = 5.5; 95% CI 1.6, 19.4) (Vaughan et al., 1986b). The majority (84%) of mobile homes in the United States at this time were reported to have mean formaldehyde exposures in excess of 100 ppb, with 22% having mean exposures in excess of 500 ppb (Breysse, 1984) as cited in WHO (IPCS, 1989). A qualitative exposure-response relationship was shown for overall mobile home exposures with the risk of nasopharyngeal cancer for working in a mobile home but not living in a mobile home (OR = 1.7; 95% CI 0.5, 5.7) being exceeded by the risk of living in a mobile home (OR = 2.8; 95% CI 1.0, 7.9). However, the greatest risk was reported for living and working in a mobile home (OR = 6.7; 95% CI 1.2, 38.9). Vaughan (1989) also reported increasing risk with duration of employment as a carpenter after lagging exposures by 15 years to account for cancer latency (χ^2^ trend = 8.65; p = 0.01 with 2 df)—especially as a carpenter in the construction industry (χ^2^ trend = 14.86; p = 0.0006 with 2 df). Carpentry is considered to be a formaldehyde-related job since many products used in construction and building trades involve exposure to formaldehyde (Vaughan et al., 1986a; Hildesheim et al., 2001). Carpentry also involves coexposure to wood dust, which is likely to be a potential confounder for NPC, as it is a potent risk factor. The potential for confounding by wood dust is evaluated in the following section. Other evidence generally consistent with an exposure-response relationship was reported by Yu et al. (2004), Hildesheim et al. (2001), and West et al. (1993). Yu et al. (2004) reported mortality Ors (MORs) for three levels of increasing cumulative exposure based on years of union membership compared to none and report MORs of 2.5, 3.41, and 3.75 (95% CI 1.12, 12.54). Hildesheim et al. (2001) reported an OR = 1.3 for less than 25 years of cumulative exposure and OR = 1.5 for more than 25 years of cumulative exposure (95% CI 0.88, 2.7, p-trend = 0.10); West et al. (1993) reported that daily use of antimosquito coils [which have been shown in experiments to emit formaldehyde concentrations of between 0.87 and 25 μg/m^3^; see (Liu et al., 2003)] had an OR = 5.9 (95% CI 1.7, 20.1), while less than daily use had an OR = 1.4.

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias may alter epidemiological findings when participation or follow-up rates are related to the probability of exposure or the outcome. However, this is an unlikely bias in the epidemiological studies of nasopharyngeal cancer, as the case-control studies evaluated exposure status without regard to outcome status and had participation levels of 85−100%. Each of the cohort studies included at least 72% of eligible participants and lost relatively few participants over the course of mortality follow-up.

The issue of potential selection bias was relevant to the results from two study populations—all classified with low confidence (Yang et al., 2005) and the three Vaughan papers (Vaughan et al., 1986a, b; Vaughan, 1989). Both Yang et al. (2005) and Vaughan (1989) with (Vaughan et al., 1986a, b) used more than 40% of case interviews completed by next of kin due to cancer mortality among cases and no proxy respondent was included for the controls. When next-of-kin is used to provide proxy information on cases, measurement error is likely to be present to some degree. If the quality of those data differs between cases and controls, this can result in selection bias if any differences are related to exposure. Hence, EPA considers that there is some risk of selection bias in the results of these studies (e.g., (Yang et al., 2005; Vaughan et al., 1986a, b; Vaughan, 1989).

Information bias may distort findings when subjects’ true personal exposures are inaccurately assigned. Differential misclassification, in which exposure status influences disease classification (or disease status influences exposure classification), can lead to bias toward or away from the null (i.e., spurious or “false positive” associations). This scenario is considered unlikely among these studies of nasopharyngeal cancer mortality because the likelihood of differential misclassification based on these study designs is low. The assignment of exposure status or calculation of exposure measures in the case-control and cohort studies was done independently of knowledge of the cause of death. Therefore, an exposure-related bias in subjects’ recall or reconstruction of their occupational histories seems unlikely.

Another aspect of information bias stems from random measurement error or nondifferential misclassification. This type of error typically will bias the risk estimate toward the null, thereby obscuring real effects by underestimating their magnitude. Given the difficulty in accurately estimating personal exposure over time or in the use of proxies to represent exposure to formaldehyde, the likelihood of random measurement error is almost certain in many studies. The implication of such information bias is that the consistently reported increases in risks of formaldehyde-related mortality may be underestimates and the true risk could be larger than was demonstrated in these epidemiological studies.

A third possible scenario for information bias could arise from systematic measurement error that is nondifferential with respect to disease. Such a scenario would be unusual in a study with exposure assessment based in industrial settings with extensive industrial hygiene data used to determine levels of exposure (Beane Freeman et al., 2013). However, a claim was made by (Marsh et al., 2002; Marsh et al., 2007a) that the exposure assessment used for the NCI formaldehyde cohort reported on by Beane Freeman et al. (2013) was 10-fold higher than those estimated by (Marsh et al., 2002; Marsh et al., 2007a). If this were true, then the same amount of observed risk in Beane Freeman et al. (2013) would be apportioned to one-tenth the same exposure, which would yield an exposure-response 10-fold greater in magnitude. The claim by (Marsh et al., 2002; Marsh et al., 2007a) suggests a one-sided uncertainty in the exposure-response reported by Beane Freeman et al. (2013), which may be 10 times more potent than reported.

Confounding is a potential bias that could arise if another cause of nasopharyngeal cancer was also associated with formaldehyde exposure. There does not appear to be any evidence of a common confounder that would provide an alternative explanation for the consistently observed association of formaldehyde exposure with increased risk of nasopharyngeal cancer seen across these studies. Chemicals and other coexposures that have not been independently associated with nasopharyngeal cancer are not expected to confound results. Other known risk factors for nasopharyngeal cancer include childhood consumption of Chinese salted fish (Yu et al., 1986), wood dust (Hildesheim et al., 2001), smoking, and alcohol consumption (Vaughan, 1996). While these other exposures may be independent risk factors for nasopharyngeal cancer, consumption of Chinese salted fish (or other dietary exposures to nitrosamines) and alcohol are unlikely to be generally related to formaldehyde exposures, and therefore, these other exposures are not expected to be consistent confounders across all of the studies. Additionally, Epstein-Barr virus is thought to be a cause of nasopharyngeal cancer due to its ubiquitous presence in nasopharyngeal cancer cases, but Hildesheim (2001) described Epstein-Barr virus as an effect modifier of the association between formaldehyde and nasopharyngeal cancer, and not as a confounder.

Wood dust may be an independent risk factor for nasopharyngeal cancer, but three studies specifically controlled for the potential confounding of the effects of wood dust on the risk of nasopharyngeal cancer and did not find wood dust to be a confounder (West et al., 1993; Vaughan et al., 2000; Hildesheim et al., 2001). Similarly, smoking was specifically controlled for in a number of studies (West et al., 1993; Vaughan et al., 1986a, b; Vaughan, 1989; Vaughan et al., 2000) and was not likely to have been a major confounder of the formaldehyde-associated results. Marsh et al. (2005) re-evaluated the association between formaldehyde exposure and NPC in the NCI cohort and reported that the majority of the cases of NPC arose in one of the 10 plants included in the cohort and that this finding suggested that there might be something specific to the experience in Plant 1 (in Wallingford , CT) that may have given rise to the excess of NPC cases there – perhaps a confounder. Marsh et al. (2007a) suggests that silversmithing may be a cause of NPC in Plant 1 and that the reported association between formaldehyde and NPC may be due to confounding; however, Beane Freeman et al. (2013) noted that the reported association for formaldehyde on the risks of NPC did not decrease when analyses adjusted for silversmithing (see Table 5 of (Marsh et al., 2007a)). The details of Table 1 in (Marsh and Youk, 2005) show the SMRs for NPC for each of the 10 plants. The two plants with the highest average intensity of formaldehyde exposure had the two highest SMR estimates for NPC. It is plausible that the observation that the majority of the cases of NPC in the NCI cohort come from Plant 1 reflects generally higher formaldehyde exposures and a larger number of people at that plant than at other plants. This overall evidence does not indicate confounding of the formaldehyde association with increased risk of NPC.

Consistency across multiple studies is demonstrated by a pattern of increased risk in different populations, exposure scenarios, and time periods. Such consistency makes unmeasured confounding an unlikely alternative explanation for the observed associations. This consistency also reduces the likelihood of chance as an alternative explanation by increasing the statistical strength of the findings through the accumulation of a larger body of similar evidence. The observations of multiple instances of very strong associations, as well as exposure-response trends with increased formaldehyde exposure using multiple metrics of exposure similarly reduce the likelihood that chance, confounding, or other biases can explain the observed association.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Consistent increases in risk observed across several studies—including results classified with high, medium, and low confidence; with higher risks among Asian populations that have higher background rates of nasopharyngeal cancer and reasonable explanations for the lack of findings in a few studies with very low background rates of nasopharyngeal cancer.
- Strength and Precision: The magnitude of the relative effect estimates varied with the quality of the exposure assessment. Nine studies out of 17 reported at least a 3-fold increase in risk and three studies reported greater than 10-fold increased risks in the highest exposure categories.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from nasopharyngeal cancer, allowing time for cancer induction, latency, and mortality.
- Dose-Response: Reported exposure-response relationships showed that multiple measures of increased exposure to formaldehyde were repeatedly associated with increased risk of dying from nasopharyngeal cancer—especially among studies primarily focused on squamous cell carcinomas.

###### Causal evaluation

The human evidence synthesis judgments strongly support a causal conclusion and are further supported by a judgment of reasonable confidence that alternative explanations are ruled out, including chance, bias, and confounding within individual studies or across studies. Although the cancer incidence and mortality data alone are sufficient for the causal conclusion supported by the human evidence synthesis judgments described above, consistent observations of genotoxicity in exfoliated buccal cells or nasal mucosal cells across several occupational studies involving diverse exposure settings (discussed under MOA below) strengthens biological plausibility, providing further support.

###### Conclusion

- The available epidemiological studies provide robust evidence of an association consistent with causation between formaldehyde exposure and increased risk of nasopharyngeal cancer.

Figure 3-19 Epidemiological studies reporting nasopharyngeal cancer risk estimates

Results are grouped by population background risk and arrayed from lowest to highest by the percentage of cases in each study’s results that were considered likely to be squamous cell carcinomas (SCC). Details of the reported results of high, medium, and low confidence are provided in the evidence table for nasopharyngeal cancer (see Table 3-32). SMR: standardized mortality ratio. PMR: proportionate mortality ratio. SPIR: Standardized Proportional Incidence Ratio. RR: relative risk. OR: odds ratio. MOR: mortality odds ratio. TSFE: time since first exposure. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 74]). For studies reporting results on multiple metrics of exposure, only the highest category of each exposure metric is presented in the figure.

Table 3-32 Epidemiological studies of formaldehyde exposure and risk of nasopharyngeal cancers

Study | Exposures | Results: effect estimate (95% CI) [# of Cases]
Reference: Beane Freeman et al. (2013); Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the United States followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. 676 workers (3%) were lost to follow-up. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine underlying cause of death from nasopharyngeal cancer (ICD-8: 147). Histological typing not reported.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency. Results were presented for 15-year lag.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2004); Beane Freeman et al. (2009); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists who took 2,000 air samples from representative job, and monitoring data from 1960 through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01−4.3). Median cumulative exposure = 0.6 ppm-years (range 0−107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 to 1980. Median length of follow-up: 42 years. Median length of employment was 2.6 years (range 1 day−47.7 years). Duration and timing since first exposure were not evaluated.; Variation in exposure:; Peak exposure:; - Level 1 (>0 to <2.0 ppm); - Level 2 (2.0 to <4.0 ppm); - Level 3 (≥4.0 ppm); Average intensity:; - Level 1 (>0 to <0.5 ppm); - Level 2 (0.5 to <1.0 ppm); - Level 3 (≥1.0 ppm); Cumulative exposure:; - Level 1 (>0 to <1.5 ppm-years); - Level 2 (1.5 to <5.5 ppm-years); - Level 3 (≥5.5 ppm-years); Duration of exposure:; - Level 1 (0 years); - Level 2 (>0 to <5 years); - Level 3 (5 to <15 years); - Level 4 (≥15 years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders and found not be confounders.; [As noted in Appendix B.3.9: There was no information on smoking, however, according to Blair et al. (1986), “The lack of a consistent elevation for tobacco-related causes of death, however, suggests that the smoking habits among this cohort did not differ substantially from those of the general population.”; Beane Freeman et al. (2013) report that among a sample of 379 cohort members, they “found no differences in prevalence of smoking by level of formaldehyde exposure.”] | Internal comparisons:
| | [underlined: Peak exposure]
| | Unexposed | RR = 4.39 (0.36−54.05) | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [1]
| | Level 2 | RR = NA | [0]
| | Level 3 | RR = 7.66 (0.94−62.34) | [7]
| | p-trend (exposed) = 0.005;; p-trend (all) = 0.10
| | [underlined: Average intensity]
| | Unexposed
| | RR = 6.79 (0.55−83.64) | | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [1]
| | Level 2 | RR = 2.44 (0.15−39.07) | [1]
| | Level 3 | RR = 11.54 (1.38−96.81) | [6]
| | p-trend (exposed) = 0.09;; p-trend (all) = 0.16
| | [underlined: Cumulative exposure]
| | Unexposed | RR = 1.87 (0.30−11.67) | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [4]
| | Level 2 | RR = 0.86 (0.10−7.70) | [1]
| | Level 3 | RR = 2.94 (0.65−13.28) | [3]
| | p-trend (exposed) = 0.06;; p-trend (all) = 0.07
| | [underlined: Duration of exposure]
| | Level 1 | RR = 1.00 (Ref. value) | [4]
| | Level 2 | RR = 0.86 (0.10−7.70) | [1]
| | Level 3 | RR = 2.94 (0.65−13.28) | [3]
| | Level 4 | RR = 2.53 (0.4−15.0) | [not given]
| | p-trend (all) = 0.4
| | External comparisons:; SMR_Unexposed_ = 1.45 (0.17−5.25) [2]; SMR_Exposed_ = 1.84 (0.84−3.49) [9]
Reference: Hauptmann et al. (2009); Population: 6,808 embalmers and funeral directors who died during 1960−1986. Identified from registries of the National Funeral Directors’ Association, licensing boards and state funeral directors’ associations, NY State Bureau of Funeral Directors, and CA Funeral Directors and Embalmers. Deaths were identified from the National Death Index. Next of kin interviews conducted for 96% of cases and 94% of controls.; Outcome definition: Death certificates used to determine UCOD from nasopharyngeal cancer (ICD-8: 147).; Design: Nested case-control study within a prospective cohort mortality study using two internal comparison groups; the first composed of those who had never embalmed (1 case and 55 controls) and the second composed of those who had fewer than 500 embalmings (five cases and 83 controls).; Analysis: Ors calculated using unconditional logistic regression adjusted for date of birth, age at death, sex, data source, and smoking. Lagged exposures were evaluated to account for cancer latency. These results are shown in table 3 of Hauptmann et al. (2009).; Results from the second internal comparison group with <500 embalmings were selected to increase statistical stability. These results are shown in table 4 of Hauptmann et al. (2009); Related studies:; Hayes et al. (1990); Walrath and Fraumeni (1983); Walrath and Fraumeni (1984); Note: The original cohorts from these three original studies were combined in Hauptmann et al. (2009) and follow-up was extended so the case-series overlap and are not independent. However, the three original cohorts used external reference groups for comparison while Hauptmann et al. (2009) selected internal controls, which were independent of the reference groups used in the original studies.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Low sensitivity (few cases). | Exposure assessment: Occupational history obtained by interviews with next of kin and coworkers using detailed questionnaires. Exposure was assessed by linking questionnaire responses to an exposure assessment experiment providing measured exposure data. Exposure levels (peak, intensity, and cumulative) were assigned to each individual using a predictive model based on the exposure data. The model explained 74% of the observed variability in exposure measurements.; Multiple exposure metrics including duration (mean = 31.3 years in cases), # of embalming, peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1932 through 1986. Duration of exposure was evaluated. Duration is also a surrogate for time because first exposure since dates of death was closely related to cessation of workplace exposures.; Variation in exposure:; - Level 1 Never embalmed; - Level 2 Ever embalmed; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | Internal comparisons:; Never embalming: OR = 1.00 (Ref. value) [2]; Ever embalming: OR = 0.1 (0.01–1.2) [2]
Reference: Hildesheim et al. (2001); Population: Male and female Taiwanese aged <75 years newly diagnosed with nasopharyngeal cancer identified between July 1991 and January 1995 from two hospitals. Participation of eligible cases was 99 and 87% for controls.; Outcome definition: Diagnosis of nasopharyngeal was confirmed by histological review with >90% diagnosed with nonkeratinizing and undifferentiated carcinomas and 9% with squamous cell carcinoma.; Design: Population-based case-control study of 375 cases of nasopharyngeal cancer. 325 controls identified from a random sample of households from a national household registration system and matched by age, sex, and area of residence.; Analysis: RRs estimated by Ors calculated by logistic regression and adjusted for age, sex, education, and ethnicity. An induction period of 10 years was also utilized to account for latency in evaluating duration of exposure.; All subjects were tested for the EBV; subset analysis based on EBV positivity (360 cases and 94 controls).; EBV seropositives defined as positive for one of the following anti-EBV antibodies known to be associated with nasopharyngeal cancer: viral capsid antigen IgA, EBV nuclear antigen one IgA, early antigen IgA, DNA binding protein IgG, and anti-Dnase IgG.; Related studies:; Yang et al. (2005); Hildesheim et al. (1997); Cheng et al. (1999); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association. | Exposure assessment: Occupational history obtained from interviews of cases and controls for jobs held for ≥1 year since age 16 and identified job title, typical activities/duties, type of industry, and tools and/or materials used.; Industrial hygienist assigned Standard Industry Classification/Standard Occupational Classification codes to jobs, assigning each a probability and intensity of exposure on a 0 (not exposed) to 9 (strong) scale. Cumulative exposure defined as the product of average intensity and duration.; Multiple exposure metrics including average intensity, average probability, cumulative, years since first exposure, and age at first exposure were evaluated.; Duration and timing: Duration and timing of exposure were evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (no); - Level 2 (yes); Duration (overall):; - Level 1 (none); - Level 2 (≤10 years); - Level 3 (>10 years); Duration (excluding 10 years before diagnosis):; - Level 1 (none); - Level 2 (≤10 years); - Level 3 (>10 years); Cumulative exposure:; - Level 1 (none); - Level 2 (<25 years); - Level 3 (≥25 years); Time since first exposure:; - Level 1 (none); - Level 2 (<20 years); - Level 3 (≥20 years); Age at first exposure:; - Level 1 (none); - Level 2 (<25 years); - Level 3 (≥25 years); Other exposures: [underlined: wood dust], solvents, and [underlined: smoking].; [[underlined: As noted in] Appendix B.3.9: The observed associations were not materially affected when controlling for wood dust, solvent exposure, or smoking.] | Internal comparisons:; All cases and controls
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.0 (Ref. value) | [301]
| | Level 2 | OR = 1.4 (0.93−2.2) | [74]
| | [underlined: Duration (overall):]
| | Level 1 | OR = 1.0 (Ref. value) | [301]
| | Level 2 | OR = 1.3 (0.69−2.3) | [31]
| | Level 3 | OR = 1.6 (0.91−2.9) | [43]
| | p-trend (exposed) = 0.08
| | [underlined: Duration (excluding 10 years before diagnosis):]
| | Level 1 | OR = 1.0 (Ref. value) | [307]
| | Level 2 | OR = 1.6 (0.89−3.0) | [34]
| | Level 3 | OR = 1.2 (0.67−2.2) | [34]
| | [underlined: Cumulative exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [301]
| | Level 2 | OR = 1.3 (0.70−2.4) | [29]
| | Level 3 | OR = 1.5 (0.88−2.7) | [45]
| | p-trend (exposed) = 0.10
| | [underlined: Time since first exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [301]
| | Level 2 | OR = 2.3 (0.95−5.8) | [19]
| | Level 3 | OR = 1.2 (0.76−2.0) | [55]
| | [underlined: Age at first exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [301]
| | Level 2 | OR = 1.3 (0.80−2.0) | [62]
| | Level 3 | OR = 3.4 (0.94−12) | [12]
| | No notable findings were reported between formaldehyde exposure and the risk of nasopharyngeal cancer when considering an induction period of 10 years.; Authors reported that the observed associations were not materially affected when analyses additionally controlled for wood dust and solvent exposure.
Reference: Hildesheim et al. (2001) | Exposure assessment: Occupational history obtained from interviews of cases and controls for jobs held for ≥1 year since age 16 and identified job title, typical activities/duties, type of industry, and tools and/or materials used.; Industrial hygienist assigned Standard Industry Classification/Standard Occupational Classification codes to jobs, assigning each a probability and intensity of exposure on a 0 (not exposed) to 9 (strong) scale. Cumulative exposure defined as the product of average intensity and duration.; Multiple exposure metrics including average intensity, average probability, cumulative, years since first exposure, and age at first exposure were evaluated.; Duration and timing: Duration and timing of exposure were evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (no); - Level 2 (yes); Duration (overall):; - Level 1 (none); - Level 2 (≤10 years); - Level 3 (>10 years); Duration (excluding 10 years before diagnosis):; - Level 1 (none); - Level 2 (≤10 years); - Level 3 (>10 years); Cumulative exposure:; - Level 1 (none); - Level 2 (<25 years); - Level 3 (≥25 years); Time since first exposure:; - Level 1 (none); - Level 2 (<20 years); - Level 3 (≥20 years); Age at first exposure:; - Level 1 (none); - Level 2 (<25 years); - Level 3 (≥25 years); Other exposures: [underlined: wood dust], solvents, and [underlined: smoking]. | Internal comparisons:; EBV positive subjects; (based on 360 cases and 94 controls)
Reference: Hildesheim et al. (2001) | | [underlined: Exposure to formaldehyde:]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 2.7 (1.2−6.2) | [# not given]
Reference: Hildesheim et al. (2001) | | [underlined: Duration (overall):]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 2.8 (0.83−9.7) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 3 | OR = 2.6 (0.87−7.7) | [# not given]
Reference: Hildesheim et al. (2001) | | [underlined: Duration (excluding 10 years before diagnosis):]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 4.7 (1.1−20) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 3 | OR = 1.7 (0.65−6.0) | [# not given]
Reference: Hildesheim et al. (2001) | | [underlined: Cumulative exposure:]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 4.0 (0.92−17) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 3 | OR = 2.2 (0.80−5.8) | [# not given]
Reference: Hildesheim et al. (2001) | | [underlined: Time since first exposure:]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 2.3 (0.52−10) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 3 | OR = 2.8 (1.1−7.6) | [# not given]
Reference: Hildesheim et al. (2001) | | [underlined: Age at first exposure:]
Reference: Hildesheim et al. (2001) | | Level 1 | OR = 1.0 (Ref. value) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 2 | OR = 2.6 (1.1−6.5) | [# not given]
Reference: Hildesheim et al. (2001) | | Level 3 | OR = 3.1 (0.39−24) | [# not given]
Reference: Hildesheim et al. (2001) | | No notable findings were reported between formaldehyde exposure and the risk of nasopharyngeal cancer when considering an induction period of 10 years.
Reference: Vaughan et al. (2000); Population: Males and females between the ages of 18 and 74 who were diagnosed with nasopharyngeal cancer between April 1987 and July 1993 and identified from five population-based cancer registries in the United States. Interviews were completed for 82% of eligible cases and 76% of eligible controls.; Outcome definition: Diagnosis of nasopharyngeal (any histological type) was based on clinical records from cancer registries. Histological typing was reported and included for analysis with 28% diagnosed with undifferentiated and nonkeratinizing carcinomas, 60% with differentiated squamous cell carcinomas, and 12% with epithelial carcinomas (not otherwise specified [NOS]).; Design: Population-based case-control study of 196 cases of nasopharyngeal cancer. 244 controls identified from random digit dialing in the same geographic regions and frequency matched by age, sex, and cancer registry.; Analysis: Ors calculated by logistic regression and adjusted for age, sex, race, SEER site, cigarette usage, proxy status, and education.; An induction period of 10 years was also utilized to account for latency in evaluating duration and cumulative exposure. Results with and without this 10-year lag period were similar.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association. | Exposure assessment: Occupational histories obtained from interviews of cases and controls and identified job title, typical activities/duties, type of industry, and start and stop dates.; Exposure was estimated by industrial hygienists by linking occupational history with participants’ self-reported exposure information.; Probability of exposure:; definitely not or unlikely (<10%),; possible (≥10 and <50%),; probable (≥50 and <90%), and; definite (≥90%).; Jobs with potential exposure assigned estimated concentration levels based on TWA8: low (<0.10 ppm), moderate (≥0.10 and <0.50 ppm), and high (≥0.50 ppm).; Multiple exposure metrics including probability of exposure and cumulative exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (never); - Level 2 (ever); Maximum exposure:; - Level 1 (<0.10 ppm); - Level 2 (0.10 to 0.50 ppm); - Level 3 (>0.50 ppm); Duration:; - Level 1 (1 to 5 years); - Level 2 (6 to 17 years); - Level 3 (>18 years); Other exposures: [underlined: Wood dust].; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] evaluated as an independent risk factor for NPC controlling for formaldehyde and it was not a risk factor in this data set.] | Internal comparisons:; All histological types:
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.0 (Ref. value) | [117]
| | Level 2 | OR = 1.3 (0.8−2.1) | [79]
| | [underlined: Maximum exposure:]
| | Level 1 | OR = 1.4 (0.8−2.4) | [60]
| | Level 2 | OR = 0.9 (0.4−2.3) | [14]
| | Level 3 | OR = 1.6 (0.3−7.1) | [5]
| | p-trend (exposed) = 0.57
| | [underlined: Duration:]
| | Level 1 | OR = 0.8 (0.4−1.6) | [24]
| | Level 2 | OR = 1.6 (0.7−3.4) | [26]
| | Level 3 | OR = 2.1 (1.0−4.5) | [29]
| | p-trend (exposed) = 0.07
| | Epithelial (NOS)
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.0 (Ref. value) | [12]
| | Level 2 | OR = 3.1 (1.0−9.6) | [12]
| | [underlined: Maximum exposure:]
| | Level 1 | OR = 4.0 (1.2−13.1) | [11]
| | Level 2 | OR = 1.5 (0.2−13.9) | [1]
| | Level 3 | no cases
| | p-trend (exposed) = 0.46
| | [underlined: Duration:]
| | Level 1 | OR = 2.0 (0.4−9.8) | [4]
| | Level 2 | OR = 4.0 (0.9−18.6) | [3]
| | Level 3 | OR = 4.2 (0.8−21.5) | [5]
| | p-trend (exposed) = 0.036
| | Differentiated Squamous Cell
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.0 (Ref. value) | [69]
| | Level 2 | OR = 1.5 (0.8−2.7) | [49]
| | [underlined: Maximum exposure:]
| | Level 1 | OR = 1.6 (0.8−3.0) | [35]
| | Level 2 | OR = 1.2 (0.4−3.3) | [10]
| | Level 3 | OR = 2.1 (0.4−12.3) | [4]
| | p-trend (exposed) = 0.32
| | [underlined: Duration:]
| | Level 1 | OR = 0.8 (0.3−2.0) | [12]
| | Level 2 | OR = 1.8 (0.7−4.3) | [17]
| | Level 3 | OR = 2.5 (1.1−5.9) | [20]
| | p-trend (exposed) = 0.033
| | Undifferentiated and nonkeratinizing
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.0 (Ref. value) | [36]
| | Level 2 | OR = 0.9 (0.4−2.0) | [18]
| | [underlined: Maximum exposure:]
| | Level 1 | OR = 1.0 (0.4−2.4) | [14]
| | Level 2 | OR = 0.5 (0.1−3.1) | [3]
| | Level 3 | OR = 1.5 (0.2−14.7) | [1]
| | p-trend (exposed) = 0.72
| | [underlined: Duration:]
| | Level 1 | OR = 0.7 (0.3−2.2) | [8]
| | Level 2 | OR = 1.0 (0.2−3.9) | [6]
| | Level 3 | OR = 1.2 (0.3−4.8) | [4]
| | p-trend (exposed) = 0.82
Reference: Vaughan et al. (2000) | Exposure assessment: Occupational histories obtained from interviews of cases and controls and identified job title, typical activities/duties, type of industry, and start and stop dates.; Exposure was estimated by industrial hygienists by linking occupational history with participants’ self-reported exposure information.; Probability of exposure:; definitely not or unlikely (<10%),; possible (≥10 and <50%),; probable (≥50 and <90%), and; definite (≥90%).; Jobs with potential exposure assigned estimated concentration levels based on 8-h TWA: low (<0.10 ppm), moderate (≥10 and <50 ppm), and high (≥50 ppm).; Multiple exposure metrics including probability of exposure and cumulative exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (never); - Level 2 (ever); Duration:; - Level 1 (1 to 5 years); - Level 2 (6 to 17 years); - Level 3 (>18 years); Cumulative exposure:; - Level 1 (0.05 to 0.40 ppm-years); - Level 2 (>0.4 to 1.10 ppm-years); - Level 3 (>1.10 ppm-years); Other exposures: [underlined: Wood dust] was evaluated but not found to be a confounder. | Internal comparisons:; Excluding undifferentiated and nonkeratinizing histological types; Possible, probable or definite exposure
Reference: Vaughan et al. (2000) | | [underlined: Exposure to formaldehyde:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 1.0 (Ref. Value | [# not given]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 1.6 (1.0−2.8) | [61]
Reference: Vaughan et al. (2000) | | [underlined: Duration:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 0.9 (0.4−2.1) | [16]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 1.9 (0.9−4.4) | [20]
Reference: Vaughan et al. (2000) | | Level 3 | OR = 2.7 (1.2−6.0) | [25]
Reference: Vaughan et al. (2000) | | p-trend (exposed) = 0.014
Reference: Vaughan et al. (2000) | | [underlined: Cumulative exposure:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 0.9 (0.4−2.0) | [15]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 1.8 (0.8−4.1) | [22]
Reference: Vaughan et al. (2000) | | Level 3 | OR = 3.0 (1.3−6.6) | [24]
Reference: Vaughan et al. (2000) | | p-trend (exposed) = 0.033
Reference: Vaughan et al. (2000) | | Probable or definite exposure
Reference: Vaughan et al. (2000) | | [underlined: Exposure to formaldehyde:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 1.0 (Ref. Value) | [# not given]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 2.1 (1.1−4.2) | [27]
Reference: Vaughan et al. (2000) | | [underlined: Duration:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 2.0 (0.8−5.0) | [12]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 3.3 (0.9−11.8) | [9]
Reference: Vaughan et al. (2000) | | Level 3 | OR = 1.6 (0.5−5.6) | [6]
Reference: Vaughan et al. (2000) | | p-trend (exposed) = 0.069
Reference: Vaughan et al. (2000) | | [underlined: Cumulative exposure:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 1.9 (0.7−4.9) | [12]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 2.6 (0.7−9.5) | [7]
Reference: Vaughan et al. (2000) | | Level 3 | OR = 2.2 (0.7−7.0) | [8]
Reference: Vaughan et al. (2000) | | p-trend (exposed) = 0.13
Reference: Vaughan et al. (2000) | | Definite exposure
Reference: Vaughan et al. (2000) | | [underlined: Exposure to formaldehyde:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = 1.0 (Ref. Value) | [# not given]
Reference: Vaughan et al. (2000) | | Level 2 | OR = 13.3 (2.5−70) | [10]
Reference: Vaughan et al. (2000) | | [underlined: Duration:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = not reported | [5]
Reference: Vaughan et al. (2000) | | Level 2 | OR = not reported | [2]
Reference: Vaughan et al. (2000) | | Level 3 | OR = not reported | [3]
Reference: Vaughan et al. (2000) | | p-trend (exposed) <0.001
Reference: Vaughan et al. (2000) | | [underlined: Cumulative exposure:]
Reference: Vaughan et al. (2000) | | Level 1 | OR = not reported | [4]
Reference: Vaughan et al. (2000) | | Level 2 | OR = not reported | [2]
Reference: Vaughan et al. (2000) | | Level 3 | OR = not reported | [4]
Reference: Vaughan et al. (2000) | | p-trend (exposed) <0.001
Reference: Vaughan et al. (2000) | | Results with and without this 10-year la period were similar.
Reference: West et al. (1993); Population: Male and female Filipinos between the ages of 11 and 83 years recruited from the Philippine General Hospital and diagnosed prior to 1992. Among 234 suspicious cases, 9% refused biopsy and were excluded and 104 were pathologically confirmed as cases (Hildesheim et al., 1992), of which 100% agreed to participate. All 104 hospital controls agreed to participate while only 77% of community controls agreed to participate (Hildesheim et al., 1992).; Outcome definition: Diagnosis of nasopharyngeal was confirmed by histological review for all cases. Histological typing not reported.; Design: Hospital-based case-control study of 104 predominantly non-Chinese cases of nasopharyngeal cancer. 205 controls (104 hospital and 101 community cases) matched on gender, age, and hospital or neighborhood.; Analysis: RRs estimated by Ors were calculated by conditional logistic regression and adjusted for education, years since first exposure to dust and exhaust fumes, smoking, antimosquito coils, herbal medicines, and diet including processed meats and fresh fish.; Related studies:; Hildesheim et al. (1992); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Occupational history obtained by interview for all participants. Occupational exposure to formaldehyde classified by industrial hygienist as likely or unlikely.; Multiple exposure metrics including analysis by length of exposure, length of exposure lagged 10 years, TSFE, and age at first exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Time since first exposure:; - Level 1 (never); - Level 2 (<25 years); - Level 3 (≥25 years); Antimosquito coil exposure:; - Level 1 (never); - Level 2 (<daily); - Level 3 (≥ daily); Length of exposure:; - Level 1 (never); - Level 2 (<15 years); - Level 3 (≥15 years); Length of exposure lagged 10 years:; - Level 1 (no); - Level 2 (<15 years); - Level 3 (≥15 years); Time since first exposure:; - Level 1 (never); - Level 2 (<25 years); - Level 3 (≥25 years); - Level 4 (≥35 years); Age at first exposure:; - Level 1 (never); - Level 2 (<25 years); - Level 3 (≥25 years); Other exposures: dust and exhaust exposure, fresh or salted fish consumption, smoking, antimosquito coils, and herbal medicines.; Note: Independent testing of six brands of East Asian mosquito coils evaluated the emission rates of carbonyl compounds in the mosquito smoke and reported that formaldehyde and acetaldehyde had the highest emission rates (Liu et al., 2003). Among the three experiments on each of the six brands, the range of formaldehyde concentrations was from 0.87 μg/m^3^ (0.7 ppb) to 25 μg/m^3^ (20 ppb).; [[underlined: As noted in] Appendix B.3.9, Control for mosquito coils may have underestimated the estimated effect of formaldehyde.] | Internal comparisons:; [underlined: Multivariate results from Table 4 in West et al.]
| | [underlined: Time since first exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [75]
| | Level 2 | OR = 1.2 (0.41−3.6) | [12]
| | Level 3 | OR = 4.0 (1.3−12.3) | [14]
| | [underlined: Antimosquito coil exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [59]
| | Level 2 | OR = 1.4 (0.64−2.8) | [24]
| | Level 3 | OR = 5.9 (1.7−20.1) | [21]
| | [underlined: Additional: Bivariate results adjusted only for dust/exhaust from Table 1]
| | [underlined: Length of exposure (bivariate):]
| | Level 1 | OR = 1.0 (Ref. value) | [75]
| | Level 2 | OR = 2.7 (1.1−6.6) | [19]
| | Level 3 | OR = 1.2 (0.48−3.2) | [8]
| | [underlined: Length of exposure lagged 10 years (bivariate):]; (Reference value included eight cases and three controls exposed only in the 10 years before diagnosis)
| | Level 1 | OR = 1.0 (Ref. value) | [83]
| | Level 2 | OR = 1.6 (0.65−3.8) | [11]
| | Level 3 | OR = 2.1 (0.70−6.2) | [8]
| | [underlined: Age at first exposure (bivariate):]
| | Level 1 | OR = 1.0 (Ref. value) | [75]
| | Level 2 | OR = 2.7 (1.1−6.6) | [16]
| | Level 3 | OR = 1.2 (0.47−3.3) | [11]
| | [underlined: Time since first exposure (bivariate):]
| | Level 1 | OR = 1.0 (Ref. value) | [75]
| | Level 2 | OR = 1.3 (0.65−3.8) | [12]
| | Level 3 | OR = 2.9 (1.1−7.6) | [14]
| | [underlined: Time since first exposure (bivariate):]
| | Level 4 | OR = 5.6 (0.58−52.9) | [5]
| | Authors noted that stronger effects were not evident among those considered most likely to have been exposed or most likely to have been exposed to high doses.
Reference: Roush et al. (1987b); Population: Males identified from the Connecticut Tumor Registry who died of any cause during 1935−1975.; Outcome definition: Diagnosis of nasopharyngeal cancer based on case registration by the Connecticut Tumor Registry. Clinical records reviewed for >75% of cases. Histological typing not reported.; Design: Population-based case-control study of 173 male cases of nasopharyngeal cancer. Controls were 605 males dying in Connecticut during the same time period, randomly selected from state death certificates.; Analysis: Ors calculated by logistic regression and adjusted for age at death, year at death, and availability of occupational information.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Occupational history obtained by city directories and death certificates, which yielded information on job, industry, employer, and year of employment.; Exposure classification scheme based on potential for formaldehyde exposure, probability of exposure for each participant and each job-industry pair, and level of exposure.; Probability of exposure defined as unexposed, possibly exposed, probably exposed, or definitely exposed.; Level of exposure estimated as zero, low (<1 ppm), and high (≥1 ppm).; Among those probably exposed to some level of formaldehyde for most of their working lifetime, the extent and level of exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure level and timing of exposure:; - Level 1 (unexposed); - Level 2 (probably exposed most of working life); - Level 3 (probably exposed most of working life and probably exposed 20+ years before death); High exposure level and timing of exposure:; - Level 1 (unexposed); - Level 2 (probably exposed most of working life and probably to high level in some year); - Level 3 (probably exposed most of working life and probably exposed to high level 20+ years before death); Other exposures: Not evaluated as potential confounders.; [[underlined: As noted in Appendix B.39]: Exposure to [underlined: wood dust] was not found to be a risk factor for all nasal cancers (NPC + SNC). This suggests a lower potential for confounding by wood dust.] | Exposure level and timing of exposure:
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.0 (0.6−1.7) | [21]
| | Level 3 | OR = 1.3 (0.7−2.4) | [17]
| | High exposure level and timing of exposure:
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.4 (0.6−3.1) | [9]
| | Level 3 | OR = 2.3 (0.9−6.0) | [7]
| | Additional: Age of Death 68+; High exposure level and timing of exposure:
| | Level 3 | OR = 4.0 (1.3−12.0) | [6]
Reference: Olsen et al. (1984); Population: Male and females linked to the Danish Cancer Registry during 1970−1982.; Outcome definition: Diagnosis of cancer of the nasopharynx based on ICD code 146 from Registry data. 9% of nasopharyngeal cases were sarcomas and 91% were carcinomas. Sarcomas were excluded but gender-specific case counts were not provided for carcinomas.; Design: Population-based case-control study of 266 cases of nasopharyngeal cancer. Three controls per case were selected for the same distributions of age, sex, and year of diagnosis as cases.; Analysis: OR calculated using programs developed by Rothman and Boice (1979).; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Employment histories from 1964 maintained by Danish Cancer Registry. Occupational exposures estimated by industrial hygienists based on industries or occupations considered to have certain or probably exposure. Authors reported that 4.2 and 0.1% of control males and females, respectively, were exposed to formaldehyde.; Duration and timing: Exposure period starting at 1964. Exposure to formaldehyde may have been between 0 and 20 years depending on when first exposed during the define exposure period.; Variation in exposure:; Occupational exposure:; - Level 1 (no exposure); - Level 2 (ever exposed); Time since first exposure:; - Level 1 (≤10 years); - Level 2 (>10 years); Coexposures: Coexposure evaluated included: wood dust, paint, lacquer, and glue.; [[underlined: As noted in] Appendix B.3.9 [underlined: Wood dust] is associated with SNC and was evaluated as a potential confounder of NPC but was not a risk factor.] | Internal comparisons:
| | Occupational exposure:
| | Men | [≈196 (91% of 215)]
| | Level 1 | RR = 1.0 (Ref. value) | [# not given]
| | Level 2 | RR = 0.7 (0.3–1.7) | [# not given]
| | Women | [≈90 (91% of 99)]
| | Level 1 | RR = 1.0 (Ref. value) | [# not given]
| | Level 2 | RR = 2.6 (0.3-21.9) | [# not given]
| | [underlined: Time since first exposure:]; No evidence of association (data not shown).
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories which produced formaldehyde. Cohort mortality followed from 1941 through 2012. Cause of deaths was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from nasopharyngeal cancer.; Design: Cohort mortality study with external comparison group with a nested case-control study.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941−1982. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers but not URT cancers.; [underlined: Asbestos] is associated with URT cancers, but not this outcome.; Other coexposures are not known risk factors for this outcome.] | External comparisons:
| | Exposed:; Observed: 1 deaths; Expected: 1.7 deaths
| | SMR_Exposed_ = 0.59 (0.03−2.90)^†^ | | [1]
| | ^†^EPA derived confidence intervals for the SMRs using Fischer’s Exact method (See Armitage and Cullis (1971); Snedecor and Cochran (1980) for nonzero SMRs and using the Mid-P method See Rothman and Boice (1979).
Reference: Meyers et al. (2013); Population: 11,043 workers in 3 U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion.; Outcome definition: Death certificates used to determine the underlying cause of death from nasopharyngeal cancer (ICD code in use at time of death). Histological typing not provided.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Stayner et al. (1985); Stayner et al. (1988); Pinkerton et al. (2004); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984 with 12−73 within each department. Formaldehyde levels across all departments and facilities were similar. Geometric TWA8 exposures ranged from 0.09−0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 to 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were not evaluated for this cancer.; Variation in exposure: Not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:
| | SMR = 0 (0−2.77) | | [0]
Reference: Siew et al. (2012); Population: All Finnish men born during 1906−1945 who participated in census and were employed in 1970 (n = 1.2 million). Vital status was “virtually complete.”; Outcome definition: Diagnosis of cancer reported to the Finnish Cancer Registry.; Design: Prospective national cohort incidence study with internal comparison groups.; Analysis: RRs calculated controlling for sex, age, socioeconomic status, period of follow-up, and smoking.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (low background rate of cancer). | Exposure assessment: Individual-level exposure estimates based on matching occupations listed in the census to the Finnish job-exposure matrix which covers major occupational exposures and provided exposure estimates for formaldehyde.; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (none); - Level 2 (any); Coexposures: [underlined: Wood dust] exposures were controlled for in analyses. | Internal comparisons:
| | Exposure to formaldehyde:
| | Level 1 | RR = 1.00 (Ref. value) | [144]
| | Level 2 | RR = 0.87 (0.34−2.20) | [5]
Reference: Yang et al. (2005); Population: Taiwanese men and women from 325 families which had two or more nonparent-offspring family members diagnosed with nasopharyngeal cancer (other first-, second-, or third-degree relatives). Cases were identified from the national tumor registry.; Outcome definition: Diagnosis of incident nasopharyngeal cancer was confirmed by histological review for all cases (n = 502). An earlier report on 375 cases from the same series reported >90% diagnosed with nonkeratinizing and undifferentiated carcinomas and 9% with squamous cell carcinoma Hildesheim et al. (2001); Design: Family-based case-control study of nasopharyngeal cancer. Cases from high-risk families were compared to two controls groups. Initial set of 375 cases reported by Cheng et al. (1999) had a 99% occupational questionnaire response rate. Similar data were available for 60% of new cases (n = 127) with the remainder considered to be missing at random. Overall case response rate is 85%.; The Family control groups consisted of up to five unaffected siblings, the parents of affected subjects, or spouses of affected cases’ children (n = 1,944; participation rate not given). Population controls (n = 327; 88% response rate) were originally matched to a subset of cases accrued at an earlier time (n = 375) matched on age, sex and residence (Cheng et al., 1999). The same population controls and cases were later augmented with additional cases to encompass the total of 502 cases.; Analysis: For the Family controls, Ors were calculated by conditional logistic regression matched on family. For the Population controls, OR’s were calculated by unconditional logistic regression controlling for age and sex; however, while population controls were originally matched on residence, residence was not controlled for in this later analysis.; Related studies:; Hildesheim et al. (1997); Hildesheim et al. (2001); Cheng et al. (1999); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Confounding possible. | Exposure assessment: Occupational history obtained from interviews of cases and controls for jobs held for ≥1 year since age 16 and identified job title, typical activities/duties, type of industry, and tools and/or materials used.; Industrial hygienist assigned Standard Industry Classification/Standard Occupational Classification codes to jobs, assigning each a probability and intensity of exposure on a 0 (not exposed) to 9 (strong) scale.; Cumulative exposure defined as the product of average intensity and duration.; Duration and timing: Duration was evaluated as a component of the cumulative exposure score. The timing of exposure was not evaluated.; Variation in exposure:; Intensity scored 0−9; Duration in years; Cumulative exposure; (Intensity*duration):; - Level 1 (none); - Level 2 (<25); - Level 3 (≥25); Other exposures:[underlined: smoking], betel nut use, wood exposure, and salted fish consumption which were not controlled for in the analysis.; [[underlined: As noted in] Appendix B.3.9: In this study, smoking was inversely associated with NPC. Since smoking is positively associated with formaldehyde, there may be negative confounding by smoking in this study.] | Internal Comparisons:; Familial cases (n = 502) compared to Family controls (n = 1,944)
| | Cumulative exposure:
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.03 (0.60−1.76) | [# not given]
| | Level 3 | OR = 1.31 (0.87−1.97) | [# not given]
| | Familial cases (n = 502) compared to population controls (n = 327)
| | Cumulative exposure (Intensity*duration):
| | Level 1 | OR = 1.00 (Ref. value) | [# not given]
| | Level 2 | OR = 1.30 (0.70−2.39) | [# not given]
| | Level 3 | OR = 4.29 (2.45−7.51) | [# not given]
Reference: Yu et al. (2004); Population: Deceased male and female restaurant workers who died during 1986−1995 and were registered as union members by four major Chinese-style restaurant workers’ unions in Hong Kong (n = 1,225).; Outcome definition: Underlying cause of death from nasopharyngeal cancer (ICD-9: 147) obtained from the Hong Kong Census and Statistics Department (n = 29). Cause of death available for more than 80% of restaurant workers. Histological typing not reported.; Design: Mortality odds ratio where cases are deaths from nasopharyngeal cancer and controls are deaths from all other causes of death after excluding cancer. Internal control group composed of other deceased kitchen workers. External control group composed of all noncancer deaths from the general population in Hong Kong.; Analysis: Mortality odds ratios (MORs) based on the internal control group were calculated by logistic regression controlling for sex, age at death, year of death, and place of origin. For the external control group, MORs were calculated by logistic regression controlling for sex, age at death, and year of death.; Related studies:; Ho et al. (2006a); EHS Consultants Ltd. (1999); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Confounding possible. | Exposure assessment: Occupational history obtained from union records. Waiters, waitresses and kitchen workers presumed to be exposed to formaldehyde based on independent studies of air quality from the kitchen exhausts of Hong Kong restaurants (Ho et al., 2006b; EHS Consultants Ltd., 1999); Note:; Ho et al. (2006b) reported time-averaged formaldehyde concentrations at Chinese restaurants in Hong Kong were reported as high as 249 ppb (306 μg/m^3^).; The Hong Kong Environmental Protection Department survey of indoor air at local restaurants reported a mean formaldehyde concentration of 162 μg/m^3^ with a high value of 975 μg/m^3^ (EHS Consultants Ltd., 1999).; Duration and timing: Duration of exposure was evaluated based on length of restaurant union membership.; Variation in exposure:; Cumulative exposure:; - Level 1 (none); - Level 2 (<15 years union membership); - Level 3 (16−24 years union membership); - Level 4 (≥25 years union membership); Other exposures: not evaluated. Wait staff exposed to other sources of formaldehyde such as environmental tobacco smoke, furniture, carpeting, and room partitions made of plywood and fiberboard, which are not shared by kitchen staff.; [[underlined: As noted in] Appendix B.3.9: Smoking was evaluated as a potential confounder because 49% of staff smoked compared to 27% of population, but it was insufficient to explain the observed effects.] | Internal Comparisons:
| | [underlined: Male and female (Waiters and waitresses)]; Wait staff cases compared to kitchen worker controls
| | MOR = 2.53 (1.01−6.36) | | [21]
| | [underlined: Male only (Waiters)]; Wait staff cases compared to kitchen worker controls
| | MOR = 2.61 (1.02−6.69) | | [17]
| | External Comparisons:
| | [underlined: Male and female (Waiters and waitresses)]; Wait staff cases compared to general Hong Kong male and female population controls
| | MOR = 3.28 (2.08−5.16) | | [21]
| | [underlined: Male only (Waiters)]; Wait staff cases compared to general Hong Kong male population controls
| | MOR = 3.02 (1.82−5.00) | | [17]
| | [underlined: Male only (Waiters)]; Cumulative exposure:
| | Level 1 | MOR = 1.00 (Ref. Value) | [3,225]
| | Level 2 | MOR = 2.50 (1.14−5.49) | [7]
| | Level 3 | MOR = 3.41 (1.56−7.45) | [7]
| | Level 4 | MOR = 3.75 (1.12−12.54) | [3]
| | [underlined: Female only (Waitresses)]; Wait staff cases compared to general Hong Kong female population controls
| | MOR = 4.58 (1.63−12.86) | | [4]
Reference: Hansen and Olsen (1995); Population: 2,041 men with cancer who were diagnosed during 1970−1984 and whose longest work experience occurred at least 10 years before cancer diagnosis. Identified from the Danish Cancer Registry and matched with the Danish Supplementary Pension Fund. Ascertainment considered complete. Pension record available for 72% of cancer cases.; Outcome definition: Nasopharyngeal cancer (ICD-7: 146) listed on Danish Cancer Registry file. Histological typing not reported.; Design: Proportionate incidence study with external comparison group.; Analysis: Standardized proportionate incidence ratio calculated as the proportion of cases for a given cancer in formaldehyde-associated companies relative to the proportion of cases for the same cancer among all employees in Denmark. Adjusted for age and calendar time.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity for NPC (few cases). | Exposure assessment: Individual occupational histories including industry and job title established through company tax records to the national Danish Product Register.; Subject were considered to be exposed to formaldehyde if: (1) they had worked in an industry known to use more than 1 kg formaldehyde per employee per year and (2) subject’s longest single work experience (job) in that industry since 1964 was ≥10 years prior to cancer diagnosis.; Duration and timing: Exposure period not stated. Based on date of diagnosis during 1970−1984, and the requirement of exposure more than 10 years prior to diagnosis, the approximate period was 1960−1974.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated for potential confounding; [[underlined: As noted in] Appendix B.3.9: While other coexposures were not evaluated, the overall correlation between coexposures in multiple occupational industries is likely to be low.] | External comparisons:; Overall (exposure to formaldehyde ≥10 years prior to cancer diagnosis)
| | SPIR = 1.3 (0.3−3.2) | | [4]
Reference: Malker et al. (1990); Population: Employed Swedish men newly diagnosed with nasopharyngeal cancer identified during 1961−1979 registered by the Swedish Cancer-Environment Registry.; Outcome definition: Microscopic confirmation obtained for 99.6% of nasopharyngeal cases. Squamous cell carcinomas constituted 48% of cases with 37% classified as unspecified carcinomas, 5% transitional cell carcinomas, and 3% adenocarcinomas.; Design: Population-based standardized incidence ratio study of 471 incidence cases of nasopharyngeal cancer compared to expected number of cases among men in occupational groups defined by employment in 1960.; Analysis: SIRs calculated as the ratio of observed to expected cases of nasopharyngeal cancer.; [underlined: Confidence in effect estimates:] ^a^; Low ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (few exposed cases). | Exposure assessment: Occupations presumed to be exposed to formaldehyde.; Duration and timing: Duration and timing of exposure were not evaluated.; Variation in exposure: Occupation and industry; Coexposures: Not evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect. | External comparisons:
| | [underlined: Occupation]
| | Glassmakers
| | SIR = 6.2 (1.58−16.87)^†^ | | [3]
| | Bookbinders
| | SIR = 6.1 (1.55−16.59)^†^ | | [3]
| | Shoemakers
| | SIR = 3.8 (1.39−8.42)^†^ | | [5]
| | [underlined: Industry]
| | Shoe repair
| | SIR = 4.0 (1.47−8.87)^†^ | | [5]
| | Fiberboard plant
| | SIR = 3.9 (1.24−9.40)^†^ | | [4]
| | ^†^EPA derived Cis using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Vaughan (1989); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System during 1980−1983. Participation for all cases was 68.7 and 80.0% for controls.; Outcome definition: Diagnosis of nasopharyngeal cancer based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates. Nonsquamous cell cancers were excluded from the study.; Design: Population-based, case-control study of 21 cases with nasopharyngeal cancer. 552 controls were identified by random digit dialing in same geographic area.; Analysis: Ors were calculated by logistic regression and adjusted for age, gender, and race. Induction periods were evaluated.; Related studies:; Vaughan et al. (1986a, 1986b); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (rare exposure). | Exposure assessment: Presumed exposure to formaldehyde. Interview-based information on lifetime occupational history by job type and industry.; Occupations evaluated for both no lag and 15-year lag time between recent exposure and diagnosis.; Duration and timing: Duration and timing of exposure were evaluated.; Variation in exposure: Occupation and industry; Duration:; - Level 1 (unexposed); - Level 2 (1 to 9 years); - Level 3 (>10 years); Other exposures: Not evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder.; ^~^50% of cases interviews completed by next of kin. May result in poorer quality exposure data and a bias toward the null.] | Internal comparisons:
| | [underlined: Carpenter (lagged 15 years)]
| | [underlined: All Industries:]
| | OR = 4.5 (1.1−18.7) | | [3]
| | [underlined: All Industries by Duration:]
| | Level 1 | OR = 1.0 (Ref. value)
| | Level 2 | OR = 1.6 (not provided)
| | Level 3 | OR = 12.4 (not provided)
| | Chi^2^ trend = 8.65 (p = 0.01)^†^
| | [underlined: Carpenter (lagged 15 years)]
| | [underlined: Construction industry:]
| | OR = 6.8 (1.6−28.2) | | [3]
| | [underlined: Construction by Duration:]
| | Level 1 | OR = 1.0 (Ref. value)
| | Level 2 | OR = 2.1 (not provided)
| | Level 3 | OR = 31.8 (not provided)
| | Chi^2^ trend = 14.86 (p = 0.0006)^†^
| | [underlined: Food Service (lagged 15 years)]
| | [underlined: All Industries:]
| | OR = 1.8 (0.6−5.7) | | [4]
| | [underlined: All Industries by Duration:]
| | Level 1 | OR = 1.0 (Ref. value)
| | Level 2 | OR = 1.6 (not provided)
| | Level 3 | OR = 4.0 (not provided)
| | Chi^2^ trend = 1.65 (p = 0.44)^†^
| | [underlined: Food Service (lagged 15 years)]
| | [underlined: Retail Trade:]
| | OR = 1.9 (0.5−6.9) | | [3]
| | [underlined: Retail Trade by Duration:]
| | Level 1 | OR = 1.0 (Ref. value)
| | Level 2 | OR = 1.4 (not provided)
| | Level 3 | OR = 9.3 (not provided)
| | Chi^2^ trend = 2.21 (p = 0.33)^†^
| | ^†^EPA computed p-value assuming 2 d.f.
Reference: Vaughan et al. (1986a); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System during 1980−1983. Participation for all cases was 68.7 and 80.0% for controls.; Outcome definition: Diagnosis of nasopharyngeal cancer based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates. Histological typing not reported; however, according to Vaughan (1989), 6 cases were nonsquamous cell cancers.; Design: Population-based, case-control study of 27 cases with nasopharyngeal cancer. 552 controls were identified by random digit dialing in same geographic area.; Analysis: Ors were calculated by logistic regression and adjusted for cigarette smoking and ethnic origin. Induction periods were evaluated.; Related studies:; Vaughan et al. (1986b); Vaughan (1989); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. | Exposure assessment: Interview-based information on lifetime occupational exposure to formaldehyde with cases, next of kin, and controls. Exposure from available hygiene data, NIOSH and other data, and NCI job-exposure linkage system.; Multiple exposure metrics including intensity, # of years exposed, and exposure score based on the sum of # years spent per job weighted by estimated formaldehyde level were evaluated. Exposure score calculated for both no lag and 15-year lag time between recent exposure and diagnosis.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Intensity of exposure:; - Level 1 (background); - Level 2 (low); - Level 3 (medium or high); Number of years exposed:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Exposure score (no lag):; - Level 1 (0 to 4); - Level 2 (5 to 19); - Level 3 (≥20); Exposure score (15-year lag):; - Level 1 (0 to 4); - Level 2 (5 to 19); - Level 3 (≥20); Other exposures: Not evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study the correlation between formaldehyde and wood dust is expected to be small and thus [underlined: wood dust] would not be expected to be a confounder.] | Internal comparisons:
| | [underlined: Intensity of exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [16]
| | Level 2 | OR = 1.2 (0.5−3.3) | [7]
| | Level 3 | OR = 1.4 (0.4−4.7) | [4]
| | [underlined: Number of years exposed:]
| | Level 1 | OR = 1.0 (Ref. value) | [16]
| | Level 2 | OR = 1.2 (0.5−3.1) | [8]
| | Level 3 | OR = 1.6 (0.4−5.8) | [3]
| | [underlined: Exposure score (no lag):]
| | Level 1 | OR = 1.0 (Ref. value) | [21]
| | Level 2 | OR = 0.9 (0.2−3.2) | [3]
| | Level 3 | OR = 2.1 (0.6−7.8) | [3]
| | [underlined: Exposure score (15-year lag):]
| | Level 1 | OR = 1.0 (Ref. value) | [21]
| | Level 2 | OR = 1.7 (0.5−5.7) | [4]
| | Level 3 | OR = 2.1 (0.4−10.0) | [2]
| | Additional:
| | Excluding Next of Kin Interviews | | [15]
| | [underlined: Exposure score (no lag):]
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.1 (0.2−5.5) | [# not given]
| | Level 3 | OR = 2.2 (0.4−10.8) | [# not given]
| | [underlined: Exposure score (15-year lag):]
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.4 (0.3−7.3) | [# not given]
| | Level 3 | OR = 3.1 (0.6−15.4) | [# not given]
Reference: Vaughan et al. (1986b); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System between 1980 and 1983. Participation for all cases was 68.7 and 80.0% for controls.; Outcome definition: Diagnosis of nasopharyngeal cancer based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates. Histological typing not reported; however, according to Vaughan (1989), 6 cases were nonsquamous cell cancers.; Design: Population-based, case-control study of 27 cases with nasopharyngeal cancer. 552 controls were identified by random digit dialing in same geographic area.; Analysis: Ors were calculated by multiple logistic regression and adjusted for cigarette smoking and ethnic origin.; Related studies:; Vaughan et al. (1986a, 1986b); Vaughan (1989); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (rare exposure). | Exposure assessment: Interview-based information on lifetime occupational history and residential history from cases, next of kin, and controls.; Multiple exposure metrics including type of dwelling (i.e., mobile home) and use of particleboard or plywood were evaluated.; Duration and timing: Exposure period since 1950. Duration of exposure was evaluated.; Variation in exposure:; Lived in a mobile home:; - Level 1 (no); - Level 2 (yes); Lived in a mobile home (lagged 15 years):; - Level 1 (no); - Level 2 (yes); Years of residence in mobile home:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Years of exposure to particleboard or plywood:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Mobile home exposures (lagged 15 years):; - Level 1 (none); - Level 2 (occupation only); - Level 3 (mobile home only); - Level 4 (both); Note: The majority (84%) of mobile homes in the United States at about this time were reported to have mean formaldehyde exposures in excess of 100 ppb, with 22% having mean exposures in excess of 500 ppb (Breysse (1984) as cited in IPCS (1989).; Coexposures: Not evaluated. Information on occupational exposures provided in Vaughan et al. (1986a).; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder.] | Internal comparisons:
| | [underlined: Lived in mobile home]:
| | Level 1 | OR = 1.0 (Ref. value) | [19]
| | Level 2 | OR = 3.0 (1.2−7.5) | [8]
| | [underlined: Lived in mobile home (lagged 15 years)]:
| | Level 1 | OR = 1.0 (Ref. value) | [24]
| | Level 2 | OR = 3.0 (0.8−11.2) | [3]
| | [underlined: Years of residence in mobile home:]
| | Level 1 | OR = 1.0 (Ref. value) | [19]
| | Level 2 | OR = 2.1 (0.7−6.6) | [4]
| | Level 3 | OR = 5.5 (1.6−19.4) | [4]
| | [underlined: Years of exposure to particleboard or plywood:]
| | Level 1 | OR = 1.0 (Ref. value) | [17]
| | Level 2 | OR = 1.4 (0.5−3.4) | [6]
| | Level 3 | OR = 0.6 (0.2−2.3) | [4]
| | [underlined: Mobile home exposures (lagged 15 years):]
| | Level 1 | OR = 1.0 (Ref. value) | [15]
| | Level 2 | OR = 1.7 (0.5−5.7) | [4]
| | Level 3 | OR = 2.8 (1.0−7.9) | [6]
| | Level 4 | OR = 6.7 (1.2−38.9) | [2]
| | Additional:
| | Excluding Next of Kin Interviews | | [15]
| | [underlined: Lived in mobile home:]
| | Level 1 | OR = 1.0 (Ref. value) | [10]
| | Level 2 | OR = 2.8 (0.9−8.8) | [5]

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9. SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Sinonasal cancer

###### Epidemiological evidence

The most specific classification of sinonasal cancer diagnosis commonly reported across the epidemiological literature has been based on the first three digits of the Seventh, Eighth or Ninth Revision of the ICD code (i.e., Malignant neoplasm of nose, nasal cavities, middle ear and accessory sinuses ICD-7/8/9: 160), although some studies did report the histological type of cancer (i.e., squamous cell carcinoma and adenocarcinoma).

Evidence of an association between formaldehyde exposure and the risk of developing or dying from sinonasal cancer was available from 20 epidemiological studies―7 case-control studies (Teschke et al., 1997; Roush et al., 1987b; Pesch et al., 2008; Olsen and Asnaes, 1986; Mayr et al., 2010; Luce et al., 2002; D’Errico et al., 2009) and 13 cohort studies (Stroup et al., 1986; Siew et al., 2012; Meyers et al., 2013; Jakobsson et al., 1997; Hayes et al., 1990; Hansen and Olsen, 1995; Coggon et al., 2014; Bertazzi et al., 1986; Beane Freeman et al., 2013);(Walrath and Fraumeni, 1983, 1984; Levine et al., 1984a; Harrington and Oakes, 1984). One additional study, (Luce et al., 2002), combined 12 other case-control studies in a pooled analysis of occupational exposures using a common protocol of standardized questionnaires and standardized exposure classifications.^28^ The results of this pooled analysis of original primary data across studies (Luce et al., 2002) are included in place of those from the 12 individual studies that are listed under “Related studies” in Table 3-33 for Luce et al. (2002). The outcome-specific evaluations of confidence in the precise effect estimate of an association from each study are provided in Appendix B.3.9. Three sets of reported results from Mayr et al. (2010), d’Errico et al. (2009), and Harrington and Oakes (1984) were classified as not informative due to multiple biases and uncertainties; for details see Appendix B.3.9. Details of the reported results of these studies are provided in the evidence table for sinonasal cancer (see Table 3-33) following the causal evaluation.

###### Consistency of the observed association

Seventeen informative studies reported risks of sinonasal cancer among study subjects with formaldehyde exposure based on occupational history. These studies examined different populations, in different locations, under different exposure settings, and used different study designs. For sinonasal cancer, it is important to consider the histological subtype or types in each report (squamous cell carcinoma, adenocarcinoma, or mixed). The study results presented in Table 3-33 (by confidence level and publication date) detail all of the reported associations. One additional study (Andjelkovich et al., 1995) reported zero cases of SNC among 3,929 U.S. workers exposed to formaldehyde over 83,064 person-years but reported no data on the number of expected cases and thus was not included here.^29^

Sinonasal cancer is exceedingly rare with expected rates of 0.6 cases per 100,000 people each year (Curado et al., 2007). Many of these cohort studies lacked the statistical sensitivity to detect an association with formaldehyde; 8 of 12 cohort studies reported zero cases in their study populations and all but 1 cohort study (Beane Freeman et al., 2013) were classified with low confidence. For such rare cancers, case-control studies can often be the most informative study design.

Of the nine studies that did observe cases of sinonasal cancer, results from six reported increased risks of sinonasal cancer that appeared to be associated with exposure to formaldehyde―four of six sets of results had been classified with medium confidence (Roush et al., 1987b; Olsen and Asnaes, 1986; Luce et al., 2002; Beane Freeman et al., 2013) and two with low confidence (Teschke et al., 1997; Hansen and Olsen, 1995). Each of the other three sets of results that did not report some increase in risk associated with formaldehyde exposure had been in the group classified with low confidence, in part due to their lack of sensitivity to detect a true effect (Siew et al., 2012; Pesch et al., 2008; Coggon et al., 2014).

As discussed in a following section on the potential for confounding, wood dust is a very strong risk factor for sinonasal cancer and because coexposure to wood dust may also be correlated with formaldehyde exposures (e.g., in carpentry and other woodworking occupations), wood dust could have been a potent confounder that might have caused the reported effects of formaldehyde to appear inflated due to positive confounding. However, the evaluation of studies in Appendix B.3.9 screened each set of results for potential confounding by wood dust and retained only those results that either controlled for coexposures to wood dust using statistical adjustment in regression analyses or by restricting analyses to workers without coexposure to wood dusts (Teschke et al., 1997; Roush et al., 1987b; Olsen and Asnaes, 1986; Luce et al., 2002; Hansen and Olsen, 1995; Beane Freeman et al., 2013), or those results from studies that were unlikely to have had occupational coexposure to wood dusts (Teschke et al., 1997; Siew et al., 2012; Coggon et al., 2014).

As can be seen in Table 3-33, and in Figure 3-20, which shows the medium confidence studies, associations were stronger for adenocarcinomas than for squamous cell carcinomas. However, both histological cell type groupings, and a mixed-type group, yielded results which were consistently elevated—with a clear demonstration of statistical significance for the adenocarcinomas.

In summary, the majority of these studies of different populations, in different locations, exposure settings, and using different study designs reported increased risks of sinonasal cancer associated with formaldehyde exposure that was unlikely to have been confounded by coexposure to wood dust.

###### Strength of the observed association

While reported relative effect estimates were largely elevated above the null value of unity (1.0) across the sets of results that detected cases of sinonasal cancer, the magnitude of the relative effect estimates varied with the quality of the exposure assessment and stratification by histological cell type. The adenocarcinoma results classified with medium confidence reported three-fold (and higher) increased risks of sinonasal cancer that appeared to be associated with higher exposure to formaldehyde after controlling for wood dust (Olsen and Asnaes, 1986; Luce et al., 2002; Hansen and Olsen, 1995). Olsen and Asnaes (1986) reported results among men for adenocarcinoma adjusted for wood dust and among those never exposed to wood dust: for “ever” vs “never” exposed to formaldehyde, the RR adjusted for ever being exposed to wood dust was 2.2 (95% CI 0.7, 7.2; 17 exposed cases) while the RR for formaldehyde among men never exposed to wood dust was 7.0 (95% CI: 1.1, 43.9; one exposed case after excluded men ever exposed to wood dust). Further restricting formaldehyde exposures to those first exposed more than 10 years prior to cancer incidence, the RR was 9.5 (95% CI 1.6, 57.8; one exposed case). Luce et al. (2002) reported increased risks for men with the highest cumulative formaldehyde exposure adjusted for wood dusts (OR = 3.0; 95% CI 1.5, 5.7; 91 cases) and for women (OR = 5.8; 95% CI 1.7, 19.4; five cases). Hansen and Olsen (1995), a low confidence study, reported that for formaldehyde exposures more than 10 years prior to cancer incidence, the Standardized Proportional Incidence Ratio was 3.0 (95% CI 1.4, 5.7; nine cases). One adenocarcinoma study that was classified with low confidence and was not able to report results by level of formaldehyde exposure, found a decreased risk of sinonasal cancer among woodworkers ever exposed to formaldehyde [Pesch et al. (2008): OR = 0.46; 95% CI 0.14, 1.54]. Pesch et al. (2008) was the only case-control study of sinonasal cancer that relied on prevalent cases and included cases accrued over a 10-year period. Since the controls in Pesch et al. (2008) were accident victims who were frequency matched on age (<60 vs. 60+ years), it is possible that the prevalent cases available at the time of the study could have been selected for survival, which may have resulted in a downward bias and may explain the inverse findings for this study.

The squamous cell carcinoma study results classified with medium confidence reported 1.5-to 2-fold increased risks of sinonasal cancer that appeared to be associated with higher exposure to formaldehyde after controlling for wood dust (Olsen and Asnaes, 1986; Luce et al., 2002), although one study result classified with low confidence found no association between sinonasal cancer in the 5% of cases “ever” exposed to formaldehyde (Siew et al. (2012): OR = 0.97; 95% CI 0.47, 2.00).

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants started prior to their diagnoses of sinonasal cancer. Three studies provided analyses of the temporal relationship showing some evidence of the effect of TSFE on the risk of dying from sinonasal cancer (Roush et al., 1987b; Olsen and Asnaes, 1986; Luce et al., 2002). Lagging formaldehyde exposures by 10 or 20 years to account for cancer latency increased the observed effects only slightly for adenocarcinoma results (Olsen and Asnaes, 1986; Luce et al., 2002) and for mixed cell type cancers (Roush et al., 1987b); but not for squamous cell carcinomas (Olsen and Asnaes, 1986). It is notable that for nasopharyngeal cancer in the tissue adjacent to the sinonasal tissues, the effect of latency on the temporal relationship between formaldehyde exposure and cancer mortality was generally longer than 25 years. Only one study of sinonasal cancer examined a lag of 20 years (Luce et al., 2002), and none examined the effect of an even longer latency. If the effect of exposure on the occurrence of sinonasal cancer took longer than the 20 years, then differences in results between lagged and unlagged exposure analyses would be consistent with the available epidemiological data.

###### Exposure-response relationship

Exposure-response relationships were not typically examined in these studies, most likely due to the rarity of cases in all of the studies except in the large, pooled study of information from 12 publications (Luce et al., 2002); see Table 3-33 for details). No results showing associations with duration of exposure were reported, but Luce et al. (2002) did state that even though their studies reported primarily on cumulative exposure, “All exposure variables (probability, maximum level, and duration) were associated with the risk of adenocarcinoma.” The majority of studies reported only comparisons of exposed versus unexposed subjects. Hansen and Olsen (1995) did report an increase in risk among formaldehyde-exposed blue-collar worker (OR = 3.0; 95% CI 1.4, 5.7) compared to exposed white-collar workers whose likely formaldehyde exposures were considered to have been lower (OR = 0.8; 95% CI 0.02, 4.4). Luce et al. (2002) pooled 196 cases of sinonasal adenocarcinoma and 432 cases of squamous cell carcinoma and was able to contrast risks in three levels of exposure probability with the risk in the unexposed. An exposure-response relationship for adenocarcinoma, controlling for coexposure to wood dust, was observed for both men and women (see Table 3-33) with the highest risks among those with the highest probability of exposure. The OR among men with the highest cumulative exposure was 3.0 (95% CI 1.5, 5.7), while it was 5.8 (95% CI 1.7, 19.4) among women. Among men with adenocarcinoma, the odds ratios adjusted for wood dust increased from OR = 0.7 (95% CI: 0.3, 1.9; six cases) among those with ‘low’ cumulative exposure, to OR = 2.4 (95% CI: 1.3, 4.5; 31 cases) among those with ‘medium’ cumulative exposure, to OR = 3.0 (95% CI: 1.5, 5.7; 91 cases) among those with ‘high’ cumulative exposure.

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias is an unlikely bias in the epidemiological studies of sinonasal cancer as the case-control studies evaluated exposure status without regard to outcome status and most had participation levels of 85_−_100%, although one case-control study of prevalent cases accrued over long periods of time had lower participation levels (67% in Pesch et al. (2008)). The cohort study (Hansen and Olsen, 1995) included 72% of eligible participants. Selection biases could obscure a truly larger effect of formaldehyde exposure in analyses based on “external” comparisons with mortality in the general population (Hansen and Olsen, 1995), but would not influence analyses using “internal” or matched comparison groups (Roush et al., 1987b; Pesch et al., 2008; Olsen and Asnaes, 1986; Luce et al., 2002). Information bias from the use of indirect exposure measures is unlikely to have resulted in bias away from the null, however random measurement error or nondifferential misclassification is almost certain to have resulted in some bias toward the null among these studies of sinonasal cancer.

Confounding is a potential bias that could arise if another cause of sinonasal cancer were also associated with formaldehyde exposure. Chemicals and other coexposures that have not been independently associated with sinonasal cancer are not expected to confound results. Other known risk factors for sinonasal cancer include wood dust (Olsen and Asnaes, 1986; Hansen and Olsen, 1995), smoking, and alcohol consumption (Vaughan, 1989). While smoking and alcohol may be independent risk factors for sinonasal cancer they are unlikely to be related to formaldehyde exposure and therefore unlikely to be across-the-board confounders. Wood dust, however, is a potential confounder as many wood-related jobs also have exposures to formaldehyde and the association between wood dust exposure and sinonasal cancer is extremely strong, with relative risks greater than 30-fold (Olsen and Asnaes, 1986).

Wood dust may be an independent risk factor for sinonasal cancer; however, the majority of investigators presented analytic results for formaldehyde among workers who were either not exposed to wood dusts (Olsen and Asnaes, 1986; Hansen and Olsen, 1995), or else controlled for the potential confounding of the effects of wood dust on the risk of sinonasal cancer and did not find wood dust to be a confounder (Luce et al., 2002).

Consistency across multiple studies is demonstrated by a pattern of increased risk in different populations, exposure scenarios, and time periods. Such consistency makes unmeasured confounding an unlikely alternative explanation for the observed associations. This consistency also reduces the likelihood of chance as an alternative explanation by increasing confidence in the statistical strength of the findings through the accumulation of a larger body of similar evidence. The observations of multiple instances of very strong associations in different settings reduce the likelihood that chance, confounding, or other biases can explain the observed associations.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Consistent increases in risk across studies (particularly for adenocarcinoma)—including four sets of results classified with medium confidence—one of which represents a large, pooled analysis of 12 case-control studies with considerably more cases and with greater detail on formaldehyde exposures.
- Strength and Precision: The magnitude of the relative effect estimates varied with the quality of the exposure assessment and by histological cell type. Two studies classified with medium confidence reported at least a 3-fold increase in risk for adenocarcinoma with lower associations for squamous cell carcinoma.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from sinonasal cancer, allowing time for cancer induction, latency, and mortality - although the rarity of this cancer limited the available data on a specific latency period.
- Dose-Response: Reported exposure-response relationship in a large, pooled analysis of 12 case-control studies showed increased exposure to formaldehyde was associated with increased risk of sinonasal cancer among people with little, or no exposure to wood dust or in analyses that controlled for wood dust.

###### Causal evaluation

The human evidence synthesis judgments sufficiently support a causal conclusion and are further supported by a judgment of reasonable confidence that alternative explanations are ruled out, including chance, bias, and confounding within individual studies or across studies. Although the cancer incidence and mortality data alone are sufficient for the causal conclusion supported by the human evidence synthesis judgments described above, consistent observations of genotoxicity in exfoliated buccal cells or nasal mucosal cells across several occupational studies involving diverse exposure settings (discussed under MOA below) strengthens biological plausibility, providing further support.

This evidence was judged to be near the borderline of robust evidence and moderate evidence, but one additional consideration increased confidence that the evidence was robust. The large, pooled analysis using a case-control study design especially suited to identify associations for this extremely rare cancer (Luce et al., 2002) was considered to be especially informative in identifying the effects of formaldehyde on the risks of sinonasal cancer and provided clear evidence of an association of increased risks of sinonasal cancer with formaldehyde exposure – especially for adenocarcinoma.

###### Conclusion

- The available epidemiological studies provide robust evidence of an association consistent with causation between formaldehyde exposure and increased risk of sinonasal cancer.

Figure 3-20 Highest (medium) confidence epidemiological studies reporting sinonasal cancer risk estimates

Results are grouped by histological type as squamous cell carcinomas, mixed cell types, or adenocarcinoma. Details of the reported results of these studies are provided in the evidence table for sinonasal cancer (see Table 3-33). SMR: standardized mortality ratio. RR: relative risk. OR: odds ratio. TSFE: time since first exposure. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 4]). For studies reporting results on multiple metrics of exposure, only the highest category of each exposure metric is presented in the figure. Note that two studies (Olsen and Asnaes, 1986; Luce et al., 2002) reported separate results for squamous cell carcinoma and adenocarcinoma and appear twice in the figure. Also note that the pooled analysis by Luce et al. (2002) includes data from 12 publications and thus represents substantially more information than a single set of results (see Table 3-33 for details).

Table 3-33 Epidemiological studies of formaldehyde exposure and risk of sinonasal cancers

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Beane Freeman et al. (2013); Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the United States followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. 676 workers (3%) were lost to follow-up. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine underlying cause of death from nasal cancer (ICD-8: 160). Histological typing not reported.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency. Results were presented for 15-year lag.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2004); Marsh et al. (2007a); Beane Freeman et al. (2009); [underlined: Confidence in effect estimates:] ^a^; MEDIUM (No appreciable bias); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A); Low sensitivity (few cases) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists who took 2,000 air samples from representative job, and monitoring data from 1960 through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01−4.3). Median cumulative exposure = 0.6 ppm-years (range 0−107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 to 1980. Median length of follow-up: 42 years. Median length of employment was 2.6 years (range 1 day−47.7 years). Duration and timing since first exposure were not evaluated.; Variation in exposure:; Peak exposure:; - Level 1 (>0 to <2.0 ppm); - Level 2 (2.0 to <4.0 ppm); - Level 3 (≥4.0 ppm); Average intensity:; - Level 1 (>0 to <0.5 ppm); - Level 2 (0.5 to <1.0 ppm); - Level 3 (≥1.0 ppm); Cumulative exposure:; - Level 1 (>0 to <1.5 ppm-years); - Level 2 (1.5 to <5.5 ppm-years); - Level 3 (≥5.5 ppm-years); Duration of exposure:; - Level 1 (0 years); - Level 2 (>0 to <5 years); - Level 3 (5 to <15 years); - Level 4 (≥15 years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders and found not be confounders.; [[underlined: As noted in] Appendix B.3.9: There was no information on smoking, however, according to Blair et al. (1986), “The lack of a consistent elevation for tobacco-related causes of death, however, suggests that the smoking habits among this cohort did not differ substantially from those of the general population.”] | Internal comparisons:
| | [underlined: Peak exposure]
| | Unexposed | RR = 5.67 (0.41−78.89) | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [1]
| | Level 2 | RR = 1.53 (0.09−24.68) | [1]
| | Level 3 | RR = 1.29 (0.08−21.23) | [1]
| | p-trend (exposed) > 0.5;; p-trend (all) = 0.37
| | [underlined: Average intensity]
| | Unexposed | RR = 4.31 (0.48−38.67) | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [2]
| | Level 2 | RR = 1.47 (0.13−16.50) | [1]
| | Level 3 | RR = N/A | [0]
| | p-trend (exposed) > 0.50;; p-trend (all) = 0.23
| | [underlined: Cumulative exposure]
| | Unexposed | RR = 3.90 (0.41−37.06) | [2]
| | Level 1 | RR = 1.00 (Ref. value) | [2]
| | Level 2 | RR = 1.22 (0.11−14.11) | [1]
| | Level 3 | RR = N/A | [0]
| | p-trend (exposed) > 0.50;; p-trend (all) = 0.28
| | External comparisons:
| | SMR_Unexposed_ = 1.93 (0.23−6.98) | | [2]
| | SMR_Exposed_ = 0.90 (0.18−2.62) | | [3]
Reference: Luce et al. (2002); Population: Males and females from seven different countries diagnosed with sinonasal cancer during 1968−1990.; Outcome definition: Diagnoses originally assessed in 12 studies. 195 cases were adenocarcinomas (169 men and 26 women) and 432 were squamous cell carcinomas (330 men and 102 women).; Design: Pooled analysis of 12 case-control studies that included 627 total cases of sinonasal cancer and 3,136 controls (2,349 men and 787 women).; Analysis: ORs calculated by unconditional logistic regression. Adenocarcinoma results in men adjusted for age, study, and cumulative exposure to wood and leather dust. All other results adjusted for age and study.; Related studies:; Zheng et al. (1992); Luce et al. (1992); Luce et al. (1993); Leclerc et al. (1994); Bolm-Audorff et al. (1990); Comba et al. (1992a); Comba et al. (1992b); Magnani et al. (1993); Merler et al. (1986); Hayes et al. (1986b); Hayes et al. (1986a); Hardell et al. (1982); Vaughan et al. (1986a, 1986b); Vaughan and Davis (1991); Vaughan (1989); Mack and Preston-Martin (unpub. data); Brinton et al. (1984); Brinton et al. (1985); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Detailed occupational history information gathered from interview questionnaires provided the basis for developing an individual’s index of exposure to formaldehyde. Standard occupational classification codes and standard industrial classification codes were used to develop a job-exposure matrix in conjunction with available industrial hygiene data. With the given occupational history information of the subjects and the job-exposure matrix, a semiquantitative index of cumulative exposure was determined for each individual calculated as the sum of the job-specific products of probability, level, and duration of exposure over the total work history. Subjects fell into one of four categories of probable exposure (unexposed, low exposure, medium exposure, or high exposure) based upon the job-exposure matrix.; Duration and timing: Latency was evaluated with 10 and 20-year lags in exposure with somewhat higher effects. Results here are without lagged exposures.; Variation in exposure:; Cumulative exposure:; - Level 1 (unexposed); - Level 2 (low); - Level 3 (medium); - Level 4 (high); Coexposures: Exposures to other compounds were identified and evaluated as potential confounders. Other occupational exposures potentially affecting the risk estimates were controlled for including [underlined: wood dust], leather dust, textile dust, flour dust, coal dust, crystalline silica, [underlined: asbestos], and man-made vitreous fibers. | Internal comparisons:
| | Adenocarcinoma
| | Men (Adjusted for wood dust)
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 0.7 (0.3−1.9) | [6]
| | Level 3 | OR = 2.4 (1.3−4.5) | [31]
| | Level 4 | OR = 3.0 (1.5−5.7) | [91]
| | Women (Not adjusted for wood dust)
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 0.9 (0.2−4.1) | [2]
| | Level 3 | no cases
| | Level 4 | OR = 6.2 (2.0−19.7) | [5]
| | Women (Adjusted for wood dust)
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 4 | OR = 5.8 (1.7−19.4) | [5]
| | Squamous cell carcinoma
| | Men (Adjusted for wood dust)
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.2 (0.8−1.8) | [43]
| | Level 3 | OR = 1.1 (0.8−1.6) | [40]
| | Level 4 | OR = 1.2 (0.8−1.8) | [30]
| | Women (Not adjusted for wood dust)
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 0.6 (0.2−1.4) | [6]
| | Level 3 | OR = 1.3 (0.6−3.2) | [7]
| | Level 4 | OR = 1.5 (0.6−3.8) | [6]
| | Additional:; Authors reported that as an additional check for potential residual confounding, the formaldehyde adenocarcinoma results for men were further adjusted for wood dust and that the results were not markedly changed.; Among women the result for high probability of formaldehyde exposure was slightly diminished (OR = 5.8; 95% CI: 1.7−19.4).
Reference: Roush et al. (1987b); Population: Males identified from the Connecticut Tumor Registry who died of any cause during 1935−1975.; Outcome definition: Diagnosis of sinonasal cancer based on case registration by the Connecticut Tumor Registry. Clinical records reviewed for >75% of cases. Histological typing not reported.; Design: Population-based case-control study of 198 male cases of sinonasal cancer. Controls were 605 males dying in Connecticut during the same time period, randomly selected from state death certificates.; Analysis: ORs calculated by logistic regression and adjusted for age at death, year at death, and availability of occupational information.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Occupational history obtained by city directories and death certificates, which yielded information on job, industry, employer, and year of employment.; Exposure classification scheme based on potential for formaldehyde exposure, probability of exposure for each participant and each job-industry pair, and level of exposure.; Probability of exposure defined as unexposed, possibly exposed, probably exposed, or definitely exposed.; Level of exposure estimated as zero, low (<1 ppm), and high (≥1 ppm).; Among those probably exposed to some level of formaldehyde for most of their working lifetime, the extent and level of exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure level and timing of exposure:; - Level 1 (unexposed); - Level 2 (probably exposed most of working life); - Level 3 (probably exposed most of working life and probably exposed 20+ years before death); High exposure level and timing of exposure:; - Level 1 (unexposed); - Level 2 (probably exposed most of working life and probably to high level in some year); - Level 3 (probably exposed most of working life and probably exposed to high level 20+ years before death); Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Exposure to [underlined: wood dust] was not found to be a risk factor for all nasal cancers (NPC + SNC). This suggests a lower potential for confounding by wood dust.] | Internal comparisons:
| | Exposure level and timing of exposure:
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 0.8 (0.5−1.8) | [21]
| | Level 3 | OR = 1.0 (0.5−1.8) | [16]
| | High exposure level and timing of exposure:
| | Level 1 | OR = 1.0 (Ref. value) | [# not given]
| | Level 2 | OR = 1.0 (0.5−2.2) | [9]
| | Level 3 | OR = 1.5 (0.6−3.9) | [7]
Reference: Olsen and Asnaes (1986); Population: Identified from the Danish Cancer Registry between 1970 and 1982. Exposures to formaldehyde and wood dust were identified too rarely to allow for risk estimation.; Outcome definition: Diagnosis of cancer of the nasal cavity (ICD-7 160.0) or sinuses (ICD-7 160.2−160.9) was histologically confirmed. Of all male cases for cancer of the nasal cavity and paranasal sinuses (n = 310), 69% were squamous cell carcinoma and lymphoepithelioma, 13% were adenocarcinoma, 6% were sarcoma, 5% were malignant melanoma, and 7% were of other histological type.; Design: Case-control study of 254 men with sinonasal cavity and paranasal cancers (215 with squamous cell carcinoma/lymphoepithelioma and 39 with adenocarcinomas). 2,465 controls with other cancers matched for gender, age, and year of diagnosis.; Analysis: The Mantel-Haenszel summary estimates of the relative risk were used to account for possible confounding since the subjects were stratified according to several variables.; Related studies:; Olsen and Jensen (1984); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Employment histories from 1964 maintained by Danish Cancer Registry estimated by industrial hygienists. Occupational exposures estimated by industrial hygienists based on industry or occupations considered to have certain or probably exposure. Authors reported that 4.2% of control males exposed to formaldehyde.; Multiple exposure metrics including known exposure and duration since first exposure were evaluated.; Duration and timing: Exposure period starting at 1964.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (Unexposed); - Level 2 (Exposed); Exposure to formaldehyde and wood dust:; - Level 1 (unexposed to either); - Level 2 (exposed to formaldehyde and unexposed to wood dust); - Level 3 (unexposed to formaldehyde and exposed to wood dust); - Level 4 (exposed to both); ≥10 years since 1st exposure to formaldehyde and wood dust:; - Level 1 (unexposed to either); - Level 2 (exposed to formaldehyde and unexposed to wood dust); - Level 3 (unexposed to formaldehyde and exposed to wood dust); - Level 4 (exposed to both); Coexposures: Exposure to [underlined: wood dust] was identified and evaluated as a potential confounder and as an effect modifier. | Internal comparisons:
| | Adenocarcinoma
| | [underlined: Exposure to formaldehyde controlling for wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [10]
| | Level 2 | RR = 2.2 (0.7−7.2) | [17]
| | [underlined: Exposure to formaldehyde and wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [8]
| | Level 2 | RR = 7.0 (1.1−43.9) | [1]
| | Level 3 | RR = 24.0 (7.6−75.6) | [2]
| | Level 4 | RR = 39.5 (22.0−70.8) | [16]
| | [underlined: ≥10 years since 1st exposure to formaldehyde and wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [6]
| | Level 2 | RR = 9.5 (1.6−57.8) | [1]
| | Level 3 | RR = 36.8 (13.5−96.0) | [3]
| | Level 4 | RR = 44.1 (22.2−87.8) | [11]
| | Squamous cell carcinoma and lymphoepithelioma
| | [underlined: Exposure to formaldehyde controlling for wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [113]
| | Level 2 | RR = 2.3 (0.9−5.8) | [13]
| | [underlined: Exposure to formaldehyde and wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [113]
| | Level 2 | RR = 2.0 (0.7−5.9) | [4]
| | Level 3 | no cases
| | Level 4 | RR = 1.6 (0.8−3.3) | [9]
| | [underlined: ≥10 years since 1st exposure to formaldehyde and wood dust:]
| | Level 1 | RR = 1.0 (Ref. value) | [81]
| | Level 2 | RR = 1.4 (0.3−6.4) | [2]
| | Level 3 | no cases
| | Level 4 | RR = 1.8 (0.7−4.4) | [6]
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories which produced formaldehyde. Cohort mortality followed from 1941 through 2012. Cause of deaths was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from nasal cancer. Histological typing not reported.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941−1982. Duration was evaluated as “more,” or “less,” than one year only among the ‘High’ exposure group. Timing since first exposure was not evaluated.; Variation in exposure:; Highest exposure level attained; - Level 1 (Background); - Level 2 (low/moderate); - Level 3 (High); Coexposures: Not evaluated. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers but not URT cancers.; [underlined: Asbestos] is associated with URT cancers, but not this outcome.; Other coexposures are not known risk factors for this outcome.] | External comparisons:
| | Overall:
| | SMR = 0.71 (0.09−2.55) | | [2]
| | Exposed:
| | Level 1 | SMR = 1.08 (0.03−6.01) | [1]
| | Level 2 | SMR = 1.01 (0.03−5.62) | [1]
| | Level 3 | SMR = 0 (0−4.03) | [0]
Reference: Meyers et al. (2013); Population: 11,043 workers in 3 U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion; Outcome definition: Death certificates used to determine both the underlying cause of death from nasal cancer (ICD-code in use at time of death). Histological typing not provided.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Pinkerton et al. (2004); Stayner et al. (1985); Stayner et al. (1988); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984 with 12−73 within each department. Formaldehyde levels across all departments and facilities were similar. Geometric TWA8 exposures ranged from 0.09 to 0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 to 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were not evaluated for this cancer.; Variation in exposure: Not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings.; [[underlined: As noted in] Appendix B.3.9: There was no information on [underlined: smoking] in this analysis, however, according to Leclerc et al. (1997), “the overall prevalence of cigarette smokers was … similar to those reported in a 1980 survey of adult Americans, in which 29.2% of females and 38.3% of males over the age of 20 were current cigarette smokers.” Therefore, confounding was considered to be unlikely. | External comparisons:
| | SMR = 0 (0−3.89) | | [0]
Reference: Siew et al. (2012); Population: All Finnish men born during 1906−1945 who participated in census and were employed in 1970 (n = 1.2 million). Vital status was “virtually complete.”; Outcome definition: Diagnosis of nasal squamous cell cancer reported to the Finnish Cancer Registry.; Design: Prospective national cohort incidence study with internal comparison groups.; Analysis: RRs calculated controlling for sex, age, socioeconomic status, period of follow-up, and smoking.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (low background rate of cancer). | Exposure assessment: Individual-level exposure estimates based on matching occupations listed in the census to the Finnish job-exposure matrix which covers major occupational exposures and provided exposure estimates for formaldehyde.; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (none); - Level 2 (any); Coexposures: [underlined: Wood dust] exposures were controlled for in formaldehyde analyses. | Internal comparisons:
| | Exposure to formaldehyde:
| | Level 1 | RR = 1.00 (Ref. value) | [158]
| | Level 2 | RR = 0.97 (0.47−2.00) | [9]
Reference: Pesch et al. (2008); Population: Male workers insured by a liability insurance association for the German wood-working industries with an occupational disease during 1994−2003. Of 129 cases of sinonasal adenocarcinoma identified, 86 cases (67%) agreed to participate (including 29 next of kin). 204 controls (75%) participated (including 69 next of kin).; Outcome definition: Cases were ever employed in German wood industries and diagnosed with histopathologically confirmed sinonasal adenocarcinoma.; Design: Insurer-based case-control study of 86 cases of sinonasal adenocarcinoma. Controls were 204 workers with accidents between home and work or falls during working shifts. Controls were frequency matched on age with 60 years as the stratification point.; Analysis: ORs calculated using logistic regressions controlling for age (<60 vs. 60+), region, interviewee, and average wood dust exposure. All temporal exposure variables were lagged by 5 years.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Selection bias possible. High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association. | Exposure assessment: Occupational history information gathered from structured questionnaires. Because next of kin information on exposure to wood additives was considered poor, the probability of exposure to formaldehyde was rated by an expert team as none, low, medium, or high.; In Germany, legislation or new formulations altered potential formaldehyde exposure in 1985 (likely lowering them). Final analyses classified exposure as unexposed, any probability of exposure before 1985, or any probability of exposure in 1985 or afterwards.; Duration and timing: Duration of formaldehyde exposure was not evaluated.; Variation in exposure:; Exposure level:; - Level 1 (unexposed); - Level 2 (any exposure <1985); - Level 3 (any exposure ≥1985); Coexposures: [underlined: Wood dust] exposures were controlled for in formaldehyde analyses. | Internal comparisons:
| | Exposure level:
| | Level 1 | OR = 1.0 (Ref. value) | [39]
| | Level 2 | OR = 0.46 (0.14−1.54) | [8]
| | Level 3 | OR = 0.94 (0.47−1.9) | [39]
Reference: Jakobsson et al. (1997); Population: 727 male employees of two plants producing stainless steel sinks and saucepans employed at least one year during 1927−1981 with minimum 15-year follow-up.; Outcome definition: Incidence of sinonasal cancer from the Swedish Tumor Registry (ICD-7:160).; Design: Cohort incidence study with external comparison group.; Analysis: SIRs calculated using sex, age, and calendar-year-expected number of cases from the national population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias with attenuation of association (Exposure Group D). Confounding possible. Low sensitivity (few cases). | Exposure assessment: Workers grind stainless steel with grinding plates made of formaldehyde resins which may release formaldehyde when heated during grinding operations.; Duration and timing: Occupational exposure preceding death during 1927−1981. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Coexposures may have included chromium, nickel, and abrasive dusts including silicon carbide, aluminum oxide, silicon dioxide, and clay.; [[underlined: As noted in] Appendix B.3.9: [underlined: Nickel] and [underlined: chromium] are associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other coexposures are not known risk factors for these outcomes.; No mention of exposure to wood dust.] | External comparisons:; Observed: 0; Expected: 0.5
| | SIR = 0 (0−8.0) | | [0]
Reference: Teschke et al. (1997); Population: 48 incident cases of nasal cancers (31% female) older than 19 years and registered by the British Columbia Cancer Agency during 1990−1992. Controls were randomly selected from age and sex strata of voter lists of the same time period (frequency matched).; 6 of original 54 cases (11%) were excluded for lack of interview as were 36 of 195 eligible controls (18%).; Outcome definition: Incidence of sinonasal cancer from the British Columbia Cancer Agency (ICD-O:160.0, 160.2, 160.9). Histological types: 23 squamous cell carcinomas (48%), seven melanomas, seven lymphomas, two adenocarcinomas (4%), two adenoid cystic carcinomas, and seven other histologies with one case each.; Design: Population-based case-control study of nasal cancer.; Analysis: ORs controlled for sex, age, and smoking.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Potential confounding. Low sensitivity (rare exposure). | Exposure assessment: Detailed occupational history information gathered from interview questionnaires.; 57 Occupational groups assessed.; Investigators discussed that textile workers, pulp and paper mill workers, and chemical and biological laboratory personnel may have formaldehyde exposures.; Duration and timing: Duration of exposure was not evaluated. Timing of exposure was evaluated for nasal cancer with results for 20-year latency presented.; Variation in exposure:; Ever employed in occupational group:; - Level 1 (never); - Level 2 (ever); Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Potential confounders for these outcomes include [underlined: chlorophenols], [underlined: acid mists], [underlined: dioxin], and [underlined: perchloroethylene] and would likely be positively correlated with formaldehyde exposure. However, on [underlined: acids mists] are associated with URT cancers.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:
| | [underlined: All histological types:]
| | Textile workers (all)
| | Level 1 | OR = 1.0 (Ref. value) | [3]
| | Level 2 | OR = 7.6 (1.4−56.6) | [6]
| | Textile workers (most recent removed)
| | Level 1 | OR = 1.0 (Ref. value) | [3]
| | Level 2 | OR = 5.0 (0.8−43.0) | [4]
| | Pulp and paper mill workers (all)
| | Level 1 | OR = 1.0 (Ref. value) | [3]
| | Level 2 | OR = 3.1 (0.4−25.4) | [3]
| | Pulp and paper mill workers (20-year lag)
| | Level 1 | OR = 1.0 (Ref. value) | [3]
| | Level 2 | OR = 3.1 (0.4−25.4) | [3]
| | Chemical and biological lab workers (all)
| | Level 1 | OR = 1.0 (Ref. value) | [8]
| | Level 2 | OR = 0.7 (0.1−4.0) | [2]
| | Chemical and biological lab workers (20-year lag)
| | Level 1 | OR = 1.0 (Ref. value) | [7]
| | Level 2 | OR = 0.9 (0.1−5.3) | [2]
| | [underlined: Squamous cell carcinoma:]
| | Textile workers (all)
| | Level 1 | OR = 1.0 (Ref. value) | [not given]
| | Level 2 | OR = 5.3 (0.2−5.3) | [not given]
Reference: Hansen and Olsen (1995); Population: 2,041 men with cancer who were diagnosed during 1970−1984 and whose longest work experience occurred at least 10 years before cancer diagnosis. Identified from the Danish Cancer Registry and matched with the Danish Supplementary Pension Fund. Ascertainment considered complete. Pension record available for 72% of cancer cases.; Outcome definition: Nasal cavity cancer (ICD-7: 160) listed on Danish Cancer Registry file. Of all male cases (n = 13), histological types of nasal cavity tumors included four squamous cell carcinomas, three adenocarcinomas, one adenoid cystic carcinoma, one melanoma, and one unknown type. Tumors of the maxillary sinus included two squamous cell carcinomas and one anaplastic carcinoma. Overall, there were six squamous cell carcinomas (46%) and two adenocarcinomas (15%).; Design: Proportionate incidence study with external comparison group.; Analysis: Standardized proportionate incidence ratio calculated as the proportion of cases for a given cancer in formaldehyde-associated companies relative to the proportion of cases for the same cancer among all employees in Denmark. Adjusted for age and calendar time.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity for NPC (few cases). | Exposure assessment: Individual occupational histories including industry and job title established through company tax records to the national Danish Product Register.; Subject were considered to be exposed to formaldehyde if: (1) they had worked in an industry known to use more than 1 kg formaldehyde per employee per year; and (2) subjects longest single work experience (job) in that industry since 1964 was ≥10 years prior to cancer diagnosis.; All subjects were stratified based on job title as either low exposure (white collar worker), above background exposure (blue collar worker), or unknown (job title unavailable).; Duration and timing: Exposure period not stated. Based on date of diagnosis during 1970−1984, and the requirement of exposure more than 10 years prior to diagnosis, the approximate period was 1960−1974.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (unknown); - Level 2 (low formaldehyde exposure); - Level 3 (formaldehyde exposure, no wood dust); - Level 4 (formaldehyde and wood dust exposure); Coexposures: Exposure to [underlined: wood dust] was evaluated as a potential confounder of sinonasal cancer. Authors excluded wood dust exposed Cases from Level 3 analyses. | External comparisons:
| | Overall (exposure to formaldehyde ≥10 years prior to cancer diagnosis)
| | SPIR = 2.3 (1.3−4.0) | | [13]
| | [underlined: Exposure to formaldehyde:]
| | Level 1 | SPIR = 1.0 (0.03−6.1) | [1]
| | Level 2 | SPIR = 0.8 (0.02−4.4) | [1]
| | Level 3 | SPIR = 3.0 (1.4−5.7) | [9]
| | Level 4 | SPIR = 5.0 (0.5−13.4) | [2]
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975−1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from sinonasal cancer (ICD-8: 160).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975−1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60−74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:; Observed: 0 cases; Expected: 1.7 cases
| | PMR = 0 (0−1.76) † | | [0]
| | Additional:
| | [underlined: By Race]
| | White | PMR = 0 (0−2.00) † | [0]
| | Non-White | PMR = 0 (0−14.98) † | [0]
| | †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979)).
Reference: Bertazzi et al. (1986); Population: 1,332 male workers ever employed in the plant between 1959 and 1980. Deaths were identified from vital statistics offices. Vital status was 98.6% complete.; Outcome definition: Nasal cancer listed as cause of death on death certificates.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, age, and calendar-year-expected number of deaths from the local population.; [underlined: Confidence in effect estimates:] ^a^; SNC: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure estimates based on occupational histories. Over the whole cohort, approximately 28% of person time was estimated to be exposed to formaldehyde.; Duration and timing: Occupational exposure preceding death during 1959−1980. Duration and timing since first exposure were not evaluated for nasal cancer.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Other exposures included [underlined: styrene], xylene, toluene, and methyl isobutyl ketone.; Styrene is associated with LHP cancers but not URT cancers.; Other coexposures are not known risk factors for this outcome.] | External comparisons:; Observed: 0; Expected: 0.0327
| | SMR = 0 (0−91.61) † | | [0]
| | †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Stroup et al. (1986); Population: 2,239 white male members of the American Association of Anatomists from 1888 to 1969 who died during 1925−1979. Death certificates obtained for 91 with 9% lost to follow-up.; Outcome definition: Cancer of the nasal cavity and sinuses listed as cause of death on death certificates.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for selection bias. Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Confounding possible for ML. Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure during 1925−1979. Median birth year was 1912. By 1979, 33% of anatomists had died. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; [Benzene is not associated with URT cancer.] | External comparisons:
| | SMR = 0 (0−7.2) | | [0]
Reference: Levine et al. (1984a); Population: 1,477 male undertakers first licensed during 1928−1977 with mortality follow-up from 1950 to 1977.; Vital status was 96% complete with cause of death available for 94%.; Outcome definition: Cancer of the nasal cavity and sinuses listed as underlying cause of death on death certificates (ICD-8: 160).; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, age, and calendar-year-expected number of deaths from the Canadian population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure during 1928−1977. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9[underlined: :] Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | Observed: 0; Expected: 0.2
| | PMR = 0 (0−14.98)† | | [0]
| | †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1984); Population: 1,007 deceased white male embalmers from the California Bureau of Funeral Directing and Embalming who died during 1925−1980. Death certificates obtained for all.; Outcome definition: Nasal cancer listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1916−1978. Birth year ranged from 1847−1959. Median age of death was 62 years. Most deaths were among embalmers with active licenses. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:; Observed: 0; Expected: 0.6
| | PMR = 0 (0−4.99)† | | [0]
| | †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1983); Population: 1,132 deceased white male embalmers licensed to practice during 1902−1980 in New York who died during 1925−1980 identified from registration files. Death certificates obtained for 75% of potential study subjects (n = 1,678).; Outcome definition: Nasal cancer listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing:; Occupational exposure preceding death during 1902−1980. Median year of birth was 1901. Median year of initial license was 1931. Median age at death was 1968. Expected median duration of exposure was 37 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:; Observed: 0; Expected: 0.5
| | PMR = 0 (0−5.99)† | | [0]
| | †Note: EPA derived CIs using the Mid-P Method (see (Rothman and Boice, 1979))

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Oropharyngeal/Hypopharyngeal cancer

###### Epidemiological evidence

Oropharyngeal and hypopharyngeal cancer is commonly reported across the epidemiological literature based on the Seventh, Eighth, or Ninth Revision of the ICD code (ICD-7/8/9: 146 and ICD-7/8/9: 148, respectively). Two studies reported specifically on hypopharyngeal cancer risks (Marsh et al., 2007a; Laforest et al., 2000), and one study reported specifically on oropharyngeal cancer risks (Marsh et al., 2007a). The results from five other studies (of three populations) allowed for grouping these two adjacent tissue sites for analyses to examine the risks of pharyngeal cancers below the nasopharynx (Vaughan et al., 1986a, b; Vaughan, 1989; Marsh et al., 2002; Gustavsson et al., 1998).

Overall, evidence describing an association between formaldehyde exposure and the risk of developing or dying from oropharyngeal/hypopharyngeal cancer was available from nine reports on six distinct study populations―four reports on three cohort studies (Meyers et al., 2013; Marsh et al., 2002; Marsh et al., 2007a; Coggon et al., 2014) and five reports on three case-control studies (Vaughan et al., 1986a, b; Vaughan, 1989; Laforest et al., 2000; Gustavsson et al., 1998). No studies with data specific to these pharyngeal cancer sites were excluded. The outcome-specific evaluations of confidence in the precise effect estimate of an association from each study are provided in Appendix B.3.9). Details of the reported results of high, medium, and low confidence are provided in the evidence table for oropharyngeal/hypopharyngeal cancer (see Table 1-34) following the causal evaluation.

###### Consistency of the observed association

The nine papers describing six populations reported the risks of oropharyngeal/hypopharyngeal cancer among study subjects who had a high likelihood of formaldehyde exposure (e.g., based on occupational history). The study results presented in Table 1-34 (by confidence level and publication date) detail all of the reported associations. Results are plotted in Figure 3-21 with results grouped by cancer site as “Oropharyngeal only,” “Undifferentiated oropharyngeal/hypopharyngeal,” or “Hypopharyngeal only.”

Based on results for overall SMRs for all workers (both exposed and unexposed) compared to external referent populations in three cohort studies (all classified with medium confidence), the effect estimates were generally elevated and ranged in magnitude between 1.1 and 2.01, but none had sufficient statistical power to exclude the null. The effect estimate for oropharyngeal cancer alone was 1.95 (Marsh et al., 2007a); 95% CI 0.63, 4.56); for the combination of oropharyngeal and hypopharyngeal cancer, the effect estimates were 1.1 (Meyers et al., 2013); 95% CI 0.40, 2.39) and 1.29 (Coggon et al., 2014); 95% CI 0.76, 2.05), respectively; and for hypopharyngeal cancer alone the effect estimate was 2.01 (Marsh et al., 2007a); 95% CI 0.87, 3.96). The only case-control study results classified with medium confidence (Laforest et al., 2000) reported effect estimates by the probability of exposure with an OR = 1.35 for “Ever” exposure to formaldehyde associated with hypopharyngeal cancer (95% CI 0.86, 2.14), but for cases with >50% probability of formaldehyde exposure the OR was 3.78 (95% CI 1.50, 9.49). The results from the two case-control studies classified with low confidence (Gustavsson et al., 1998), and the three Vaughan reports (Vaughan et al., 1986a, b; Vaughan, 1989) were largely surrounding the null.

Subgroup analyses provide some indication of increased risk when a latency period was accounted for. Increased risks of oropharyngeal/hypopharyngeal cancer were also reported by Marsh et al. (2002) among workers with at least 10 years of formaldehyde exposure (SMR = 2.48; 95% CI 0.63, 6.75)—especially for those with at least 10 years of exposures greater than 0.2 ppm (SMR = 4.94; 95% CI 1.25, 13.38). After excluding those with <10% probability of being exposed to formaldehyde, Laforest et al. (2000) found that for those with at least 20 years of exposure, the OR was 2.70 (95% CI 1.08, 6.73).

Overall, the findings were heterogeneous. Results from the two case-control studies classified with low confidence Gustavsson et al. (1998) and the Vaughan papers (Vaughan et al., 1986a, b; Vaughan, 1989) did not show increased risks, although Gustavsson et al. (1998) did not assess differences by exposure concentration or duration. The Vaughan analyses (Vaughan et al., 1986a, b; Vaughan, 1989) did examine differences in exposures but did not observe consistently increased risks. As with the Gustavsson et al. (1998) study, the Meyers et al. (2013) cohort study did not assess differences in exposure concentration or duration and found only a minimally increased risk. Coggon et al. (2014) did report results for duration greater than 1 year but did not observe consistently increased risks, and Vaughan et al. (1986b) did not observe an increased risk of oropharyngeal/hypopharyngeal cancer for living more than 10 years in a mobile home (although the corresponding OR for NPC was 5.5). Two other results from Marsh et al. (2002) and Laforest et al. (2000) did observe increased risks associated with >10 and >20 years of exposure duration.

###### Strength of the observed association

Summary effect estimates (SMR or RR) ranged from 1.01 (Gustavsson et al., 1998) to slightly more than a doubling of the relative effect estimates (Marsh et al., 2007a). Only one study (Marsh et al., 2007a) reported a summary effect estimate (for cancers of the oropharynx, hypopharynx and unspecified pharynx) that excluded the null (OR = 1.98; 95% CI 1.17, 3.15). The magnitude of the relative effect estimates varied but did not appear to depend on the specific non-nasopharyngeal cancer site. Marsh et al. (2002) provided specific SMRs for oropharyngeal (ICD-9: 146), hypopharyngeal (ICD-9: 148), and “pharyngeal cancer, unspecified” (ICD-9: 149), which were very similar at 1.95, 2.01, and 2.11 respectively. Exposure level-specific estimated risks ranged from 0.8 for the highest residential duration of exposure to particleboard (Vaughan et al., 1986b) up to 4.94 for workers exposed to concentrations of formaldehyde greater than 200 ppb for more than 10 years.

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants started before their diagnoses of oropharyngeal/hypopharyngeal cancer. Only one study (Vaughan et al., 1986a) reported results for formaldehyde exposure lagged by 15 years to account for latency and did not find higher risks. It is notable that for nasopharyngeal cancer in the tissue neighboring the oropharynx, the latency between formaldehyde exposure and cancer mortality was generally longer than 25 years (see Section 3.2.5 Nasopharyngeal cancer); thus, studies without similar follow-up time and appropriately lagged exposure may be insufficiently sensitive.

Marsh et al. (2002) reported on the effect of time since first employment in a formaldehyde-related occupation as a proxy for latency. Those data (see Table 3-34) indicate that the risk of workers with 20−29 years at a chemical plant producing or using formaldehyde had an SMR = 1.50 (95% CI 0.48, 3.61), while workers with more than 30 years’ tenure had a higher risk (SMR = 2.69; 95% CI 1.31, 4.94). Extended duration of exposure can also be a reasonable proxy for latency. Compared to unexposed workers, Laforest et al. (2000) reported increasing risks with increasing duration of exposure for all workers (regardless of their probability of exposure) reaching an OR = 1.51 (95% CI 0.78, 2.92) for those with more than 20 years’ exposure to formaldehyde with an even more pronounced effect of extended duration among those workers with the higher probabilities of exposure (OR = 2.70; 95% CI 1.08, 6.73).

###### Exposure-response relationship

Only three study populations were available for evaluating exposure-response relationships between formaldehyde and increased risk of oropharyngeal/hypopharyngeal cancer. The paired studies by Vaughan et al. (1986a, b) did not show evidence of an exposure-response relationship with the same exposure metrics as they did for nasopharyngeal cancer. Conversely, Laforest et al. (2000) reported a clear exposure-response trend for increasing probability of formaldehyde exposure (p < 0.005) and for increasing duration of formaldehyde exposure among subjects with at least 10% probability of exposure (p < 0.04), with some indication of a trend with increasing cumulative exposure (p < 0.14). Marsh et al. (2002) also found higher risks at higher durations of exposure.

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias is an unlikely bias in the epidemiological studies of oropharyngeal/hypopharyngeal cancer as the cohort study followed by (Marsh et al., 2002; Marsh et al., 2007a) included 98% of eligible participants and lost relatively few participants over the course of mortality follow-up, and the case-control study by Laforest et al. (2000) evaluated exposure status without regard to outcome status and had participation levels of 80% for cases and 86% for controls. Information bias is unlikely to have resulted in bias away from the null; however, random measurement error or nondifferential misclassification is almost certain to have resulted in some bias toward the null among these studies of oropharyngeal/hypopharyngeal cancer. For example, regarding one particular analysis from Marsh et al. (2002), the authors reported risks for exposure greater than 700 ppb of formaldehyde that might have been useful for comparison with the risk for exposure of greater than 200 ppb; however, by comparing risk above 700 ppb to risk among “unexposed” workers (with exposures ranging from 0 to 699 ppb), information bias was likely induced, which may have attenuated that risk and made the inclusion of this result unsuitable for exposure-response evaluation.

Confounding is a potential bias that could arise if another cause of oropharyngeal/hypopharyngeal cancer is also associated with formaldehyde exposure. There does not appear to be any evidence of confounding that would provide an alternative explanation for the observed association of formaldehyde exposure with increased risk of oropharyngeal/hypopharyngeal cancer seen across these studies. Chemical and other coexposures that have not been independently associated with oropharyngeal/hypopharyngeal cancer are not expected to confound results. Other known risk factors for oropharyngeal/hypopharyngeal cancer include smoking and alcohol consumption (Vaughan, 1996). While these other exposures may be independent risk factors for oropharyngeal/hypopharyngeal cancer, smoking and alcohol consumption are unlikely to be generally related to occupational and residential formaldehyde exposures and are therefore unlikely to be across-the-board confounders. This is especially true for studies comparing risks within a cohort of workers who may be more similar to each other in smoking status than they are compared to an external population. This is relevant to the NCI cohort which Beane Freeman (2013) noted had a high prevalence of current or former smokers across all levels of formaldehyde exposure (i.e., smoking prevalence was likely independent of formaldehyde exposure and not a confounder). However, the Marsh reports on one plant in this cohort (Marsh et al., 2002; Marsh et al., 2007a) compared the risk of those workers to an external population which might have had lower prevalences of smoking allow for a greater potential for confounding by smoking in those reports.

Overall, the findings were heterogeneous with no association observed in study results of low confidence and a mix of positive associations and null findings in study results of medium confidence. For oropharyngeal/hypopharyngeal cancer, the lack of consistency weakens the etiologic conclusion. However, the observations of increased risks across multiple medium confidence results, as well as two identified exposure-response relationships with increased duration of formaldehyde exposure is suggestive of an association.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Results were heterogeneous with five study reporting results near the null—but three medium confidence studies with more specific exposure metrics showing some significantly increase risks.
- Strength and Precision: Variable strength of the association across studies and metrics with two medium confidence studies reporting 3-fold to 5-fold increases in risk among groups with the highest exposure probability or duration and several studies reporting results near the null.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from oropharyngeal/hypopharyngeal cancer, allowing time for cancer induction, latency, and mortality—although the rarity of this cancer limited the available data on a specific latency period.
- Dose-Response: Reported exposure-response relationships using multiple metrics of exposure from one study showed that increased exposure to formaldehyde was associated with increased risk of developing oropharyngeal/hypopharyngeal cancer.

###### Causal evaluation

The human evidence synthesis judgment is suggestive of an association, but does not sufficiently support a causal conclusion. Although consistent observations of genotoxicity in exfoliated buccal cells or nasal mucosal cells have been observed across several occupational studies, these data were not interpreted as sufficient to provide additional biological plausibility for these associations or strengthen the judgment on the human evidence of cancers of the oropharynx and, more indirectly, the hypopharynx.

###### Conclusion

- The available epidemiological studies provide slight evidence of an association between formaldehyde exposure and increased risk of oropharyngeal/hypopharyngeal cancer.

Figure 3-21 Epidemiological studies reporting oropharyngeal or hypopharyngeal cancer risk estimates

Results are grouped by cancer site as oropharyngeal only, oropharyngeal grouped with hypopharyngeal and unspecified pharyngeal, or hypopharyngeal only. Details of the reported results of high, medium, and low confidence are provided in the evidence table for oropharyngeal/hypopharyngeal cancer (see Table 3-34). SMR: standardized mortality ratio. RR: relative risk. OR: odds ratio. CE: cumulative exposure. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 6]). For studies reporting results on multiple metrics of exposure, only the highest category of each exposure metric is presented in the figure. Data from (Marsh et al., 2002; Marsh et al., 2007a) are based on the same study subjects; however, exposure-response data were only included in the 2002 study, and the 2007 study had more recent comparisons with external referents.

Table 3-34 Studies of formaldehyde exposure and risk of cancer of oropharynx/hypopharynx

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories which produced formaldehyde. Cohort mortality followed from 1941 through 2012. From Coggon et al. (2003), cause of death was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete and only 1.1% lost to follow-up through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from pharyngeal cancer minus deaths from nasopharyngeal cancer.; Design: Cohort mortality study with external comparison group with a nested case-control study.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies: Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941−1982. Duration was evaluated as more, or less, than one year only among the “High” exposure group. Timing since first exposure was not evaluated.; Variation in exposure:; - Duration of “High” exposures; - Level 1 (Background); - Level 2 (<1 year); - Level 3 (1 year or more); Coexposures: Not evaluated. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: Styrene is associated with LHP cancers but not URT cancers.; Asbestos is associated with URT cancers, but not this outcome.; Other coexposures are not known risk factors for this outcome.] | External comparisons:; For NPC (p. 1,307 in Coggon et al.):; - 1 observed case with exposure above background vs. 1.7 expected.; For all pharyngeal cancers (see Table 3 in Coggon et al.):; - 17 cases observed in all subjects vs. 14.1 expected.; - 11 cases with exposures above background v. 9.2 expected.; Therefore, for OHPC:; - 10 observed cases with exposure above background vs. 7.5 expected.; - 16 observed cases in all subjects vs. 12.4 expected.; SMR_All Subjects_ = 1.29 (0.76−2.05)† [16]; SMR_Exposed_ = 1.33 (0.68−2.38)† [10]; Internal comparisons:; Since the 1 NPC case had “low/Moderate exposure,” the all-pharyngeal-cancer results in Table 6 in Coggon et al. (2014) for “High exposure” are OHPC.; Duration of ‘High’ exposures; - Level 1 OR = 1.00 (Ref. value) [10]; - Level 2 OR = 0.63 (0.13−3.03) [3]; - Level 3 OR = 0.81 (0.22−3.05) [6]; †Note: EPA derived CIs using the Mid-P Method (see (Rothman and Boice, 1979))
Reference: Meyers et al. (2013); Population: 11,043 workers in 3 U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion.; Outcome definition: Death certificates used to determine the underlying cause of death from other/unspecified pharymgeal cancer (ICD code in use at time of death). Histological typing not provided.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Pinkerton et al. (2004); Stayner et al. (1985); Stayner et al. (1988); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984. Geometric TWA8 exposures ranged from 0.09−0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 to 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were not evaluated for this cancer.; Variation in exposure: Not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:; - SMR = 1.1 (0.40−2.39) [6]
Reference: Marsh et al. (2007a); Marsh et al. (2002); Population: 7,328 workers employed at formaldehyde-using plant in the United States followed from 1945 through 2003. Vital status was identified from the National Death Index, private businesses, or state and local agencies, and was 98% complete and 1.4% lost to follow-up. Among the deceased, the cause of death was available for 95.2%.; This population was from one plant from Beane Freeman et al. (2009).; Outcome definition: Death certificates used to determine underlying cause of death from oropharyngeal/hypopharyngeal cancer according to the ICD-9 codes (146, 148).; Design: Cohort mortality study with external comparison groups.; Analysis: SMRs calculated by dividing the number of observed deaths by the number of expected deaths. Expected deaths were the product of death rate (at national, state, or local level) and person-years accumulated by all the members of the cohort. SMRs made age, race, gender, and period specific to reduce bias and to generate tabular information by these variables. Mortality was compared with death rates in two Connecticut counties and the United States. These results are shown in Table 2 in Marsh et al. (2007a).; Related studies:; (Beane Freeman et al., 2009); Hauptmann et al. (2004); (Marsh et al., 1994; Marsh et al., 1996; Marsh et al., 2002); [underlined: Confidence in effect estimates:] ^a^; OHPC together:; MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. | Exposure assessment: Worker-specific exposure from job-exposure matrix based on available sporadic sampling data from 1965 to 1987, job descriptions, and verbal job descriptions by plant personnel and industrial hygienists.; Exposures ranked on a 7-point scale with exposure range assigned to each rank. 17% of jobs validated with company monitoring data; remaining 83% based on professional judgment. Assumed pre-1965 exposure levels same as post-1965 levels.; Exposure assessment did not include the same industrial hygiene sampling conducted by Stewart et al. (1986) used in the (Beane Freeman et al., 2009; Beane Freeman et al., 2013) analyses which included this plant.; Exposure estimates generated by this method were 10 times lower on average than those estimated by the NCI.; Multiple exposure metrics including, known exposure, average intensity and cumulative exposures were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure: None.; Coexposures: Coexposures previously identified in Marsh et al. (1996) included product and nonproduct particulates and airborne pigments.; [[underlined: As noted in] Appendix B.3.9: Marsh et al. (2002) attempted to evaluate smoking but data were incomplete. No other potential confounders were evaluated.; (Beane Freeman et al., 2009; Beane Freeman et al., 2013) evaluated 11 potential confounders among a set of 10 plants that included this one and did not find any confounding.] | External comparisons:; [underlined: Oropharyngeal cancer]; U.S. referent SMR = 1.95 (0.63−4.56) [5]; County referent SMR = 1.71 (0.56−4.00) [5]; [underlined: Hypopharyngeal cancer]; U.S. referent SMR = 2.01 (0.87−3.96) [3]; County referent SMR = 1.88 (0.81−3.70) [3]; [underlined: Pharyngeal cancer excluding nasopharyngeal]; U.S. referent SMR = 1.98 (1.17−3.15) [16]; County referent SMR = 1.71 (1.01−2.72) [16]
Reference: Marsh et al. (2002); Population: 7,328 workers employed at formaldehyde-using plant in the United States followed from 1945 through 1998. Vital status was identified from the National Death Index, private businesses, or state and local agencies, and was 98.4% complete and 1.6% lost to follow-up.; This population was from one plant from (Beane Freeman et al., 2009; Beane Freeman et al., 2013).; Outcome definition: Death certificates used to determine underlying cause of death from oropharyngeal/hypopharyngeal cancer according to the ICD-9 codes (146, 148).; Design: Cohort mortality study with external comparison groups.; Analysis: SMRs calculated by dividing the number of observed deaths by the number of expected deaths. Expected deaths were the product of death rate (at national, state, or local level) and person-years accumulated by all the members of the cohort. SMRs made age, race, sex, and period specific to reduce bias and to generate tabular information by these variables. Mortality was compared with death rates in two Connecticut counties and the United States. These results are shown in Table 2 in Marsh et al. (2002).; Related studies:; (Beane Freeman et al., 2009; Beane et al., 2013); (Marsh et al., 1994; Marsh et al., 1996; Marsh et al., 2007a); [underlined: Confidence in effect estimates:] ^a^; Oro- alone & Hypo- alone:; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Worker-specific exposure from job-exposure matrix based on available sporadic sampling data from 1965 to 1987, job descriptions, and verbal job descriptions by plant personnel and industrial hygienists. Exposures ranked on a 7-point scale with exposure range assigned to each rank. 17% of jobs validated with company monitoring data; remaining 83% based on professional judgment. Assumed pre-1965 exposure levels same as post-1965 levels.; Exposure assessment did not include the same industrial hygiene sampling conducted by Stewart et al. (1986) used in the (Beane Freeman et al., 2009; Beane Freeman et al., 2013) analyses which included this plant,; Exposure estimates generated by this method were 10 times lower on average than those estimated by the NCI.; Multiple exposure metrics including, known exposure, average intensity and cumulative exposures were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure (from Table 3 in Marsh et al. (2002)):; For all variations in exposure:; - Level 1 (unexposed); Exposure to formaldehyde:; - Level 2 (exposed); Duration of exposure to formaldehyde:; - Level 2 (0 to <1 years); - Level 3 (1 to 9 years); - Level 4 (>10 years); Cumulative exposure to formaldehyde:; - Level 2 (0 to <0.004 ppm-years); - Level 3 (0.004 to 0.219 ppm-years); - Level 4 (>0.22 ppm-years); Average intensity exposure:; - Level 2 (0 to <0.03 ppm); - Level 3 (0.03 to 0.159 ppm); - Level 4 (>0.16 ppm); Exposure to formaldehyde >0.2 ppm:; - Level 2 (exposed); Duration of exposure to >0.2 ppm:; - Level 2 (0 to <1 years); - Level 3 (1 to 9 years); - Level 4 (>10 years); Coexposures: Coexposures previously identified in Marsh et al. (1996) included product and nonproduct particulates and airborne pigments. | External comparisons:; [underlined: Oropharyngeal cancer]; U.S. referent SMR = 2.17 (0.71−5.07) [5]; County referent SMR = 1.80 (0.58−4.19) [5]; [underlined: Hypopharyngeal cancer]; U.S. referent SMR = 2.25 (0.46−6.58) [3]; County referent SMR = 1.52 (0.31−4.43) [3]; [underlined: Pharyngeal cancer, unspecified]; U.S. referent SMR = 2.11 (0.85−4.35) [7]; County referent SMR = 1.89 (0.76−3.89) [7]; [underlined: Oropharyngeal/Hypopharyngeal cancer]; [underlined: Exposure to formaldehyde:]; - Level 1 SMR = 1.24‡ (0.21−4.10)† [2]; - Level 2 SMR = 1.83‡ (1.02−3.05)† [13]; [underlined: Duration of formaldehyde exposure:]; - Level 1 SMR = 1.24‡ (0.21−4.10)† [2]; - Level 2 SMR = 1.75‡ (0.77−3.46)† [7]; - Level 3 SMR = 1.58‡ (0.40−4.32)† [3]; - Level 4 SMR = 2.48‡ (0.63−6.75)† [3]; [underlined: Cumulative exposure to formaldehyde:]; - Level 1 SMR = 1.24‡ (0.21−4.10)† [2]; - Level 2 SMR = 3.20‡ (1.17−7.10)† [5]; - Level 3 SMR = 1.28‡ (0.40−3.07)† [4]; - Level 4 SMR = 1.56‡ (0.50−3.77)† [4]; [underlined: Average intensity exposure:]; - Level 1 SMR = 1.24‡ (0.15−4.49)† [2]; - Level 2 SMR = 1.96‡ (0.72−4.33)† [5]; - Level 3 SMR = 1.91‡ (0.49−5.20)† [3]; - Level 4 SMR = 1.69‡ (0.62−3.74)† [5]; [underlined: Exposure to formaldehyde >0.2 ppm:]; - Level 1 SMR = 1.51‡ (0.21−4.10)† [6]; - Level 2 SMR = 2.01‡ (1.02−3.05)† [9]; [underlined: Duration of exposure to >0.2 ppm:]; - Level 1 SMR = 1.51‡ (0.21−4.10)† [6]; - Level 2 SMR = 1.72‡ (0.47−4.16)† [4]; - Level 3 SMR = 1.30‡ (0.22−4.29)† [2]; - Level 4 SMR = 4.94‡ (1.25−13.38)† [3]; ‡Note: EPA derived SMRs for the combination of oropharyngeal, hypopharyngeal and unspecified pharyngeal cancer by subtracting the number of observed and expected nasopharyngeal cancer from the same counts for all pharyngeal cancers.; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Marsh et al. (2002) | Exposure assessment: Worker-specific exposure from job-exposure matrix based on available sporadic sampling data from 1965 to 1987, job descriptions, and verbal job descriptions by plant personnel and industrial hygienists. Exposures ranked on a 7-point scale with exposure range assigned to each rank. 17% of jobs validated with company monitoring data; remaining 83% based on professional judgment. Assumed pre-1965 exposure levels same as post-1965 levels.; Exposure estimates generated by this method were 10 times lower on average than those estimated by the NCI.; Multiple exposure metrics including, known exposure, average intensity, and cumulative exposures were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in work history (from Table 3 in Marsh et al. (2002)):; For all variations in exposure:; - Level 1 (unexposed); Exposure to formaldehyde:; - Level 2 (exposed); Work history:; - Level 1 (short-term workers: <1 year); - Level 2 (long-term workers: 1+ year); Year of hire:; - Level 1 (1941−1946); - Level 2 (1947−1956); - Level 3 (1957+); Duration of employment:; - Level 1 (unexposed); - Level 2 (<1 year); - Level 3 (1+ years); Time since first employment:; - Level 1 (<20 year); - Level 2 (20−29 years); - Level 3 (30+ years) | External comparisons:; [underlined: Exposure to formaldehyde >0.7 ppm:]; - Level 1 SMR = 1.86‡ (1.01−3.16)† [12]; - Level 2 SMR = 1.46‡ (0.37−3.98)† [3]; [underlined: Duration of exposure to >0.7 ppm:]; - Level 1 SMR = 1.86‡ (1.01−3.16)† [12]; - Level 2 SMR = 1.49‡ (0.25−4.93)† [2]; - Level 3 SMR = 1.41‡ (0.07−6.95)† [1]; [underlined: Work history:]; - Level 1 SMR = 2.82‡ (1.31−5.37)† [8]; - Level 2 SMR = 1.70‡ (0.74−3.37)† [7]; [underlined: Year of hire:]; - Level 1 SMR = 0.46‡ (0.11−10.73)† [1]; - Level 2 SMR = 2.49‡ (1.35−4.23)† [12]; - Level 3 SMR = 1.14‡ (0.19−3.78)† [2]; [underlined: Duration of employment:]; - Level 1 SMR = 1.83‡ (0.85−3.47)† [8]; - Level 2 SMR = 1.77‡ (0.56−4.27)† [4]; - Level 3 SMR = 1.62‡ (0.41−4.41)† [3]; [underlined: Time since first employment:]; - Level 1 SMR = 0.82‡ (0.14−2.71)† [2]; - Level 2 SMR = 1.50‡ (0.48−3.61)† [4]; - Level 3 SMR = 2.69‡ (1.31−4.94)† [9]; ‡Note: EPA derived SMRs for the combination of oropharyngeal, hypopharyngeal and, unspecified pharyngeal cancer by subtracting the number of observed and expected nasopharyngeal cancer from the same counts for all pharyngeal cancers.; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Laforest et al. (2000); Population: Males diagnosed with primary hypopharyngeal squamous cell cancers between January 1989 and May 1991 and identified through 15 French hospitals. Interviews completed for 79.5% of eligible cases and 86% of eligible controls.; Outcome definition: Diagnosis of laryngeal and hypopharyngeal cancers was histologically confirmed.; Design: Hospital-based case-control study of 201 hypopharyngeal cancers. 296 hospital controls frequency matched on age.; Analysis: ORs were calculated by unconditional logistic regression and adjusted for age, alcohol, and smoking. Induction periods of 5, 10, and 15 years was also utilized to account for latency in evaluating risk.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association | Exposure assessment: Occupational history obtained by interview. Exposure assessment based on job-exposure matrix that included level and probability of exposure, duration, and cumulative exposure to formaldehyde.; Multiple exposure metrics including known exposure, probability of exposure, and cumulative exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; All subjects; Exposure to formaldehyde:; - Level 1 (never exposed); - Level 2 (ever exposed); Probability of exposure:; - Level 1 (never exposed); - Level 2 (<10%); - Level 3 (10 to 50%); - Level 4 (>50%); Duration of exposure:; - Level 1 (never exposed); - Level 2 (<7 years); - Level 3 (7 to 20 years); - Level 4 (>20 years); Cumulative exposure:; - Level 1 (never exposed); - Level 2 (low, <0.02); - Level 3 (medium, 0.02 to 0.09); - Level 4 (high, >0.09); Subjects with a probability of exposure >10%; Exposure to formaldehyde:; - Level 1 (never exposed); - Level 2 (ever exposed); Duration of exposure:; - Level 1 (never exposed); - Level 2 (≤7 years); - Level 3 (7 to 20 years); - Level 4 (>20 years); Cumulative exposure:; - Level 1 (never exposed); - Level 2 (low); - Level 3 (medium); - Level 4 (high); Other exposures: [underlined: asbestos], coal dust, leather dust, [underlined: wood dust], flour dust, silica, and textile dust.; [[underlined: As noted in] Appendix B.3.9: Of these, only coal dust significantly increased the risk of hypopharyngeal cancer in this study but coal dust and asbestos were controlled for in the OHPC analysis.] | Internal comparisons:; All subjects; [underlined: Exposure to formaldehyde:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 1.35 (0.86−2.14) [83]; [underlined: Probability of exposure:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 1.08 (0.62-1.88) [42]; - Level 3 OR = 1.01 (0.44-2.31) [15]; - Level 4 OR = 3.78 (1.50-9.49) [26]; - p-trend (all) < 0.005; [underlined: Cumulative exposure:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 1.03 (0.51-2.07) [23]; - Level 3 OR = 1.57 (0.81-3.06) [32]; - Level 4 OR = 1.51 (0.74-3.10) [28]; [underlined: Duration of exposure:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 1.09 (0.50-2.38) [18]; - Level 3 OR = 1.39 (0.74-2.62) [37]; - Level 4 OR = 1.51 (0.78-2.92) [28]; Subjects with a probability of exposure >10%; [underlined: Exposure to formaldehyde:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 1.74 (0.91-3.34) [41]; Cumulative exposure:; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 0.78 (0.11-5.45) [3]; - Level 3 OR = 1.77 (0.65-4.78) [13]; - Level 4 OR = 1.92 (0.86-4.32) [25]; - p-trend (all) < 0.14; [underlined: Duration of exposure:]; - Level 1 OR = 1.00 (Ref. value) [118]; - Level 2 OR = 0.74 (0.20-2.68) [6]; - Level 3 OR = 1.65 (0.67-4.08) [19]; - Level 4 OR = 2.70 (1.08-6.73) [16]; - p-trend (all) < 0.04; Introduction of induction times as described did not substantially change the results.
Reference: Gustavsson et al. (1998); Population: Males between the ages of 40 and 79 years residing in Sweden identified by hospitals reports or regional cancer registries during 1988−1990. Interviews completed for 90% of cases and 85% of controls.; Outcome definition: Diagnosis of cancer of the pharyngeal cancer based on ICD-9 codes 146 (oropharynx) and 148 (hypopharynx) but not including code 147 (nasopharynx) on weekly reports from departments of otorhinolaryngology, oncology, and surgery and from regional cancer registries.; Design: Community-based, case-control study of 138 cases of squamous cell carcinoma of the oropharynx/hypopharynx. 641 controls were randomly identified from population registers and frequency matched by region and age.; Analysis: RRs were calculated by unconditional logistic regression and adjusted for region, age, drinking, and smoking.; [underlined: Confidence in effect estimates:] ^a^; SUMMARY:; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (exposure was rare). | Exposure assessment: Occupational history obtained by interview and yielded information on all jobs held >1 year, starting and stopping times, job title, tasks, and company. Histories reviewed by industrial hygienist who coded jobs based on intensity and probability of exposure to 17 occupational factors. Exposure assessments estimated intensity on a 4-point scale and probability of exposure as point estimates. Cumulative exposure calculated as the product of exposure intensity, probability of exposure, and duration of exposure, and by adding contributions over entire work history.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (never); - Level 2 (ever); Other exposures: polycyclic aromatic hydrocarbons, [underlined: asbestos], general dust, [underlined: wood dust], quartz, metal dust, oil mist, welding fumes, manmade mineral fibers, paper dust, textile dust, hexavalent chromium, phenoxy acids, nickel, acid mist, and leather dust.; [[underlined: As noted in] Appendix B.3.9: Of these, only leather dust was a risk factor but only five cases were exposed.] | Internal comparisons:; [underlined: Exposure to formaldehyde:]; - Level 1 OR = 1.00 (Ref. value) [# not given]; - Level 2 OR = 1.01 (0.49−2.07) [13]
Reference: Vaughan (1989); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System during 1980−1983. Participation for all cases was 68.7 and 80.0% for controls.; Outcome definition: Diagnosis of pharyngeal cancer based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates. Nonsquamous cell cancers were excluded from the study.; Design: Population-based, casecontrol study of 183 cases with oro pharyngeal/hypopharyngeal cancer. 552 controls were identified by random digit dialing in same geographic area.; Analysis: ORs were calculated by logistic regression and adjusted for gender, cigarette smoking, and alcohol. Induction periods were evaluated.; Related studies:; Vaughan et al. (1986a, 1986b); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde. Interview-based information on lifetime occupational history by job type and industry. Occupations evaluated for both no lag and 15-year lag time between recent exposure and diagnosis.; Duration and timing: Duration and timing of exposure were evaluated.; Variation in exposure: Occupation and industry; Duration:; - Level 1 (unexposed); - Level 2 (1 to 9 years); - Level 3 (>10 years); Other exposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder.] | Internal comparisons:; [underlined: Carpenter (lagged 15 years)]; - [underlined: All Industries:]; - OR = 1.3 (0.5−3.4) [11]; - [underlined: All Industries by Duration:]; - Level 1 OR = 1.0 (Ref. value); - Level 2 OR = 0.6 (not given); - Level 3 OR = 2.2 (not given); [underlined: Carpenter (lagged 15 years)]; - [underlined: Construction industry:]; - OR = 1.8 (0.7−4.8) [10]; - [underlined: Construction by Duration:]; - Level 1 OR = 1.0 (Ref. value); - Level 2 OR = 0.7 (not given); - Level 3 OR = 6.2 (not given)
Reference: Vaughan et al. (1986a); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System between 1980 and 1983. Participation for all cases was 69 and 80% for controls. Interviews completed for 71% of cases and 83% of controls.; Outcome definition: Diagnosis of oropharynx/hypopharynx cancer (ICD codes 146 and 148) based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates.; Design: Population-based, casecontrol study of 205 incident cases with cancer of the oropharynx/hypopharynx including unspecified pharyngeal sites. 552 controls were identified by random digit dialing in same geographic area.; Analysis: ORs were calculated by logistic regression and adjusted for cigarette smoking, alcohol consumption, sex, and age. An induction period of 15 years was also utilized to account for latency in evaluating exposure score.; Related studies: Vaughan et al. (1986b); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. | Exposure assessment: Interview-based information on lifetime occupational exposure to formaldehyde with cases, next of kin, and controls. Exposure from available hygiene data, NIOSH and other data, and NCI job-exposure linkage system.; Multiple exposure metrics including intensity, # of years exposed, and exposure score based on the sum of # years spent per job weighted by estimated formaldehyde level were evaluated. Exposure score calculated for both no lag and 15-year lag time between recent exposure and diagnosis.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Intensity:; - Level 1 (background); - Level 2 (low); - Level 3 (medium); - Level 4 (high); Number of years exposed:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Exposure score (no lag):; - Level 1 (0 to 4); - Level 2 (5 to 19); - Level 3 (≥20); Exposure score (15-year lag):; - Level 1 (0 to 4); - Level 2 (5 to 19); - Level 3 (≥20); Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder.] | Internal comparisons:; [underlined: Intensity:]; - Level 1 OR = 1.0 (Ref. value) [147]; - Level 2 OR = 0.8 (0.5−1.4) [41]; - Level 3 OR = 0.8 (0.4−1.7) [13]; - Level 4 OR = 0.6 (0.1−2.7) [4]; [underlined: Number of years exposed:]; - Level 1 OR = 1.0 (Ref. value) [147]; - Level 2 OR = 0.6 (0.3−1.0) [32]; - Level 3 OR = 1.3 (0.7−2.5) [26]; [underlined: Exposure score (no lag):]; - Level 1 OR = 1.0 (Ref. value) [170]; - Level 2 OR = 0.6 (0.3−1.2) [14]; - Level 3 OR = 1.5 (0.7−3.0) [21]; [underlined: Exposure score (15-year lag):]; - Level 1 OR = 1.0 (Ref. value) [174]; - Level 2 OR = 0.9 (0.4−1.8) [16]; - Level 3 OR = 1.3 (0.6−3.1) [15]
Reference: Vaughan et al. (1986b); Population: Males and females between the ages of 20 and 74 years residing in a 13-county area identified by the Washington State Cancer Surveillance System between 1980 and 1983. Participation for all cases was 68.7 and 80.0% for controls. Interviews completed for 71% of cases and 83% of controls.; Outcome definition: Diagnosis of oropharynx/hypopharynx cancer (ICD codes 146 and 148) based on review of hospital medical records, surveillance of private radiotherapy and pathology practices, and state death certificates.; Design: Population-based, casecontrol study of 205 incident cases with cancer of the oropharynx/hypopharynx including unspecified pharyngeal sites. 552 controls were identified by random digit dialing in same geographic area with one control per case randomly selected from all the eligible persons in the household and frequency matched for gender and age.; Analysis: ORs were calculated by multiple logistic regression and adjusted for cigarette smoking, alcohol consumption, sex, and age.; Related studies:; Vaughan et al. (1986a); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. | Exposure assessment: Interview-based information on lifetime occupational history and residential history from cases, controls, and next of kin for deceased cases.; Multiple exposure metrics including type of dwelling (i.e., mobile home) and use of particleboard or plywood were evaluated.; Duration and timing: Exposure period since 1950. Duration of exposure was evaluated.; Variation in exposure:; Residence in mobile home:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Years of exposure to particleboard or plywood:; - Level 1 (0 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Coexposures: Not evaluated. Information of occupational exposures provided in Vaughan et al. (1986a); [[underlined: As noted in] Appendix B.3.9: [underlined: Wood dust] is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder.] | Internal comparisons:; [underlined: Residence in mobile home:]; - Level 1 OR = 1.0 (Ref. value) [177]; - Level 2 OR = 0.9 (0.5−1.8) [21]; - Level 3 OR = 0.8 (0.2−2.7) [7]; [underlined: Years of exposure to particleboard:]; - Level 1 OR = 1.0 (Ref. value) [137]; - Level 2 OR = 1.1 (0.7−1.9) [40]; - Level 3 OR = 0.8 (0.5−1.4) [28]

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

##### Laryngeal cancer

###### Epidemiological evidence

Evidence describing an association between formaldehyde exposure and the risk of developing or dying from laryngeal cancer was available from 18 studies—13 cohort studies (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Meyers et al., 2013; Levine et al., 1984a; Jakobsson et al., 1997; Hayes et al., 1990; Hansen et al., 1994; Hansen and Olsen, 1995; Coggon et al., 2014; Beane Freeman et al., 2013; Band et al., 1997; Andjelkovich et al., 1995) and five case-control studies (Wortley et al., 1992; Shangina et al., 2006; Laforest et al., 2000; Gustavsson et al., 1998; Berrino et al., 2003). Two reported results were classified as not informative. Berrino et al. (2003) was classified as not informative due to likely confounding by highly correlated coexposures, one of which was a stronger risk factor for laryngeal cancer in that study than was formaldehyde (i.e., solvents). Hansen et al. (1994) was classified as not informative due to likely information bias stemming from the rarity of exposure among cases in that cohort. The outcome-specific evaluations of confidence in the precise effect estimate of an association from each study are provided in Appendix B.3.9. Details of the reported results of high, medium, and low confidence are provided in the evidence table for laryngeal cancer (see Table 3-35) following the causal evaluation.

###### Consistency of the observed association

The results of the 16 informative studies were not consistent. The study results presented in Table 3-35 (by confidence level and publication date) detail all of the reported associations. Only one set of results was classified with high confidence (Beane Freeman et al., 2013), and those results surrounded the null with a modest increase in risk overall with SMR = 1.23 (95% CI 0.91, 1.67), and at the highest level of average intensity of exposure a RR = 1.73 (95% CI 0.83, 3.60), and conversely, a modest decrease in risk at the highest level of peak exposure with RR = 0.72 (95% CI 0.32, 1.65), and a stronger decreased risk at the highest level of duration of exposure with RR = 0.33 (95% CI 0.10, 1.11). Of the five sets of results classified with medium confidence (Wortley et al., 1992; Shangina et al., 2006; Laforest et al., 2000; Hayes et al., 1990; Coggon et al., 2014), only two reported clearly increased risks; Shangina et al. (2006) showed an association with the highest level of cumulative exposure (OR = 3.12, 95% CI 1.23, 7.91) and Wortley et al. (1992) showed an association among those with at least 10 years of exposure and the highest peak exposures (OR = 4.3, 95% CI 1.0, 18.7). Coggon et al. (2014) found modestly increased risk for the cohort as a whole (SMR = 1.22, 95% CI 0.76, 1.84) and higher risks among those workers who had ever been “highly” exposed (SMR = 1.96, 95% CI 0.98, 3.50). They did not find greater risk among those who had been “highly” exposed for more than 1 year (SMR = 1.30, 95% CI 0.39, 4.38). The results from Laforest et al. (2000) and Hayes et al. (1990) did not show consistently increased risks. The study results classified with low confidence were consistently around the null. Results are plotted in Figure 3-22.

###### Strength of the observed association

Summary effect estimates for the association between formaldehyde exposure and the relative effect estimates of developing or dying from laryngeal cancer ranged from 0.33 to 4.3 and generally clustered around the null. The study results classified with low confidence were all limited to summary estimates without examination of exposures levels within the exposed study subjects. The results classified with medium confidence differentiated the risks by levels of exposure, and these results showed somewhat higher effect estimates among the most highly exposed groups, but these effect estimates were largely less than a doubling of risk. There were two results of medium confidence that reported more than a tripling of risk (Wortley et al., 1992; Shangina et al., 2006). However, the one set of results classified with high confidence (Beane Freeman et al., 2013) did not report a consistent pattern of increased risk.

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants started prior to their diagnoses of laryngeal cancer and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and done in a blinded fashion with respect to outcome status. While several of the studies did report results with lagged exposures to account for potential latency effects, none of the 16 studies provided details of analyses of a temporal relationship between the timing of exposure using different lags and the diagnoses of laryngeal cancer or deaths from laryngeal cancer. However, Shangina et al. (2006) did state that a 20-year lag in exposure was assessed but did not report those details for formaldehyde; and Wortley et al. (1992) reported that a 10-year lag in exposure ‘only slightly’ increased the estimated effects.

###### Exposure-response relationship

The strongest evidence of an exposure-response was reported by Shangina et al. (2006), who found that among cases of “Ever” exposed to formaldehyde, the OR = 1.68 (95% CI 0.85, 3.31), those cases with the highest tertile of cumulative exposure had an OR = 3.12 (95% CI 1.23, 7.91). Shangina et al. (2006) also reported suggestions of trends for increased risk with increasing tertiles of duration of exposure (p < 0.06) and with increasing tertile of cumulative exposure (p < 0.07). Wortley et al. (1992) also found higher risks among the most highly exposed with an OR = 4.3 (95% CI 1.0, 18.7). However, Beane Freeman et al. (2013) did not find consistent evidence of an exposure-response relationship for increasing peak exposure (p > 0.5), for increasing average intensity (p = 0.44), but did find a significant trend (p = 0.02) with cumulative exposure that may have been decreasing in nature with lower risks at higher exposures.

###### Potential impact of selection bias, information bias, confounding bias, and chance

For laryngeal cancer, the reliance of cohort studies on death certificates to detect cancers with relatively high survival underestimated the actual incidence of those cancers. Five-year survival rates are about 60% (see Appendix B.3.9). This may have resulted in undercounting of incident cases and underestimates of effect estimates in cohort studies compared to general populations. Selection bias could have somewhat obscured a truly larger effect of formaldehyde exposure on the risk of death from laryngeal cancer and may explain the preponderance of effect estimates near the null. The case-control studies Shangina et al. (2006), Laforest et al. (2000), Gustavsson et al. (1998), and Wortley et al. (1992), because they recruited incident cases, were less prone to such a bias. Information bias may distort findings when subjects’ true personal exposures are inaccurately assigned. Random measurement error typically results in a bias toward the null, thereby obscuring any real effect by underestimating the effect’s magnitude. Confounding is another potential bias that could arise if another cause of laryngeal cancer was statistically associated with formaldehyde exposure. However, there does not appear to be any evidence of negative confounding that could have obscured a real but unobserved effect. Overall, bias is considered to be an unlikely alternative cause for the isolated reports of increased risks of laryngeal cancer associated with formaldehyde exposures.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: The results of the 16 informative studies were not consistent – although there were suggestive associations reported for two medium confidence studies.
- Strength and Precision: Variable strength of the association across studies and metrics with two medium confidence studies reporting 3-fold increases in risk among groups with the highest exposure probability or duration and several studies reporting results near the null.
- Coherence: Where associations were observed, there were biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from laryngeal cancer, allowing time for cancer induction, latency, and mortality - although the rarity of this cancer limited the available data on a specific latency period.
- Dose-Response: Suggestive exposure-response relationships of increased risk with increased formaldehyde exposure in one study, but lack of support for exposure-response from other studies including the single set of results classified with high confidence which found a significant downward trend in risks with increasing exposure.

###### Causal evaluation

The human evidence synthesis judgments is inconsistent. The moderate survival rate for laryngeal cancer (60%) may indicate that mortality data are not as good a proxy for incidence data for this cancer type.

###### Conclusion

- The available epidemiological studies provide indeterminate evidence of an association between formaldehyde exposure and increased risk of oropharyngeal/hypopharyngeal cancer.

Figure 3-22 Epidemiological studies reporting laryngeal cancer risk estimates

Details of the reported results of high, medium, and low confidence are provided in the evidence table for laryngeal cancer (see Table 3-35). For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 1]). For studies reporting results on multiple metrics of exposure, only the highest category of each exposure metric is presented in the figure. Note that the confidence intervals for Band et al. (1997) are 90%, not 95%. Abbreviations: SMR = standardized mortality ratio; RR = relative risk; OR = odds ratio; SPIR = standardized proportional incidence ratio.

Table 3-35 Epidemiological studies of formaldehyde exposure and risk of laryngeal cancer

Study | Exposures | Results: effect estimate (95% CI); [# of cases]
Reference: Beane Freeman et al. (2013); Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the United States followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. 676 workers (3%) were lost to follow-up. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine underlying cause of death from laryngeal cancer (ICD-8: 161). Histological typing not reported.; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency. Results were presented for 15-year lag.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Hauptmann et al. (2004); Beane Freeman et al. (2009); [underlined: Confidence in effect estimates:]^a^ HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists who took 2,000 air samples from representative job, and monitoring data from 1960 through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01–4.3). Median cumulative exposure = 0.6 ppm-years (range 0–107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 to 1980. Median length of follow-up: 42 years. Median length of employment was 2.6 years (range 1 day–47.7 years). Duration and timing since first exposure were not evaluated.; Variation in exposure:; Peak exposure:; - Level 1 (>0 to <2.0 ppm); - Level 2 (2.0 to <4.0 ppm); - Level 3 (≥4.0 ppm); Average intensity:; - Level 1 (>0 to <0.5 ppm); - Level 2 (0.5 to <1.0 ppm); - Level 3 (≥1.0 ppm); Cumulative exposure:; - Level 1 (>0 to <1.5 ppm-years); - Level 2 (1.5 to <5.5 ppm-years); - Level 3 (≥5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders. | Internal comparisons:; [underlined: Peak exposure]
| | Unexposed | RR = 0.79 (0.25–2.48) | [6]
| | Level 1 | RR = 1.00 (Ref. value) | [17]
| | Level 2 | RR = 1.52 (0.76–3.05) | [16]
| | Level 3 | RR = 0.72 (0.32–1.65) | [9]
| | p-trend (exposed) > 0.50;; p-trend (all) > 0.50
| | [underlined: Average intensity]
| | Unexposed | RR = 0.89 (0.29–2.75) | [6]
| | Level 1 | RR = 1.00 (Ref. value) | [21]
| | Level 2 | RR = 1.25 (0.57–2.76) | [9]
| | Level 3 | RR = 1.73 (0.83–3.6) | [12]
| | p-trend (exposed) = 0.44;; p-trend (all) = 0.39
| | [underlined: Cumulative exposure]
| | Unexposed | RR = 0.67 (0.22–2.00) | [6]
| | Level 1 | RR = 1.00 (Ref. value) | [29]
| | Level 2 | RR = 1.01 (0.49–2.11) | [10]
| | Level 3 | RR = 0.33 (0.10–1.11) | [3]
| | p-trend (exposed) = 0.02;; p-trend (all) = 0.03
| | External comparisons:
| | SMR_Unexposed_ = 0.93 (0.42–2.08) | | [6]
| | SMR_Exposed_ = 1.23 (0.91–1.67) | | [42]
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories that produced formaldehyde. Cohort mortality followed from 1941 through 2012. Cause of deaths was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from laryngeal cancer.; Design: Cohort mortality study with external comparison group with a nested case-control study.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:]^a^ MEDIUM ↓; High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941–1982. Duration was evaluated as more, or less, than one year only among the “High” exposure group. Timing since first exposure was not evaluated.; Variation in exposure:; Highest exposure level attained; - Level 1 (Background); - Level 2 (low/moderate); - Level 3 (High); Duration of “High” exposures; - Level 1 (Background); - Level 2 (<1 year); - Level 3 (1 year or more); Coexposures: Not evaluated. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers but not URT cancers.; [underlined: Asbestos] is associated with URT cancers, including laryngeal cancer.; Authors stated that the extent of coexposures was expected to be low.; Potential for confounding may be mitigated by low coexposures.; Other coexposures are not known risk factors for this outcome.] | External comparisons:
| | SMR = 1.22 (0.76–1.84) | | [22]
| | Highest exposure level attained
| | Level 1 | SMR = 0.33 (0.04–1.20) | [2]
| | Level 2 | SMR = 1.40 (0.64–2.66) | [9]
| | Level 3 | SMR = 1.96 (0.98–3.50) | [11]
| | Internal comparisons:; Highest exposure level attained
| | Level 1 | OR = 1.00 (Ref. value) | [14]
| | Level 2 | OR = 1.20 (0.53–2.73) | [17]
| | Level 3 | OR = not given | [22]
| | Duration of “High” exposures
| | Level 1 | OR = 1.00 (Ref. value) | [14]
| | Level 1 | OR = 2.02 (0.65–6.27) | [14]
| | Level 2 | OR = 1.30 (0.39–4.38) | [8]
Reference: Shangina et al. (2006); Population: Males between the ages of 15 and 79 years residing in four European countries that were diagnosed with laryngeal cancer during 1999–2002 and identified by study centers in Romania, Poland, Russia, and Slovakia.; Outcome definition: Diagnosis of laryngeal cancer was histologically or cytologically confirmed and included topographic subcategories from ICD-O code C32 (glottis, supraglottis, subglottis, laryngeal cartilage, overlapping lesion of the larynx, and larynx, unspecified).; Design: Multicenter case-control study of 316 laryngeal cancer cases. 728 hospital controls were frequency matched by age.; Analysis: ORs were calculated by unconditional logistic regression and adjusted for age, country, tobacco smoking, and alcohol consumption. An induction period of 20 years was also utilized to account for latency in evaluating risk.; [underlined: Confidence in effect estimates:]^a^ MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Low sensitivity (exposure was rare). | Exposure assessment: Occupational histories obtained by interview and yielded information on all jobs held >1 year. A general questionnaire obtained information of job titles, tasks, industries, starting and stopping times, full-time/part-time status, working environments, and specific exposures. A specific questionnaire was completed for employment in defined jobs or industries.; Exposure assessment based on expert judgment of reported task descriptions. Exposure scored according to intensity, frequency, and confidence.; Multiple exposure metrics including known exposure and cumulative exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (never); - Level 2 (ever); Cumulative exposure (tertiles):; - Level 1 (Tertile 1 unspecified); - Level 2 (Tertile 2 unspecified); - Level 3 (≥22,700 mg/m^3^-hrs); Duration of exposure (tertiles):; - Level 1 (Tertile 1 unspecified); - Level 2 (Tertile 2 unspecified); - Level 3 (Tertile 3 unspecified); Definitions for levels of exposure for duration of exposure to formaldehyde and cumulative exposure not provided by authors except for the lower bound of Tertile 3 for cumulative exposure.; Other exposures: Not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9: Other exposures that were found to be risk factors included dusts of “hard alloys” (16 cases) and chlorinated solvents (15 cases).; Hard-alloy dust and chlorinated solvents were each found in fewer than 6% of cases, the correlation between them is considered to be small enough to make confounding unlikely.] | Internal comparisons:; [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.00 (Ref. value) [298]
| | Level 2 | OR = 1.68 (0.85–3.31) | [18]
| | [underlined: Duration of exposure:]
| | p-trend (all) = 0.06
| | [underlined: Cumulative exposure:]
| | Level 1 | Unspecified
| | Level 2 Unspecified
| | Level 3 | OR = 3.12 (1.23–7.91)
| | p-trend (all) = 0.07
| | [underlined: Duration of exposure:]
| | Level 1 | Unspecified
| | Level 2 Unspecified
| | Level 3 | Unspecified
| | p-trend (all) = 0.06
| | No notable findings were reported between formaldehyde exposure and the risk of laryngeal cancer when considering an induction period of 20 years.
Reference: Laforest et al. (2000); Population: Males diagnosed with primary laryngeal squamous cell cancers between January 1989 and May 1991 and identified through 15 French hospitals. Interviews completed for 79.5% of eligible cases and 86% of eligible controls.; Outcome definition: Diagnosis of laryngeal was histologically confirmed.; Design: Hospital-based case-control study of 296 laryngeal cancers. 296 hospital controls frequency matched on age.; Analysis: ORs were calculated by unconditional logistic regression and adjusted for age, alcohol, and smoking. Induction periods of 5, 10, and 15 years was also utilized to account for latency in evaluating risk.; [underlined: Confidence in effect estimates:]^a^ MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. | Exposure assessment: Occupational history obtained by interview. Exposure assessment based on job-exposure matrix that included level and probability of exposure, duration, and cumulative exposure to formaldehyde.; Multiple exposure metrics including known exposure, probability of exposure, and cumulative exposure were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; All subjects; Exposure to formaldehyde:; - Level 1 (never exposed); - Level 2 (ever exposed); Probability of exposure:; - Level 1 (never exposed); - Level 2 (<10%); - Level 3 (10 to 50%); - Level 4 (>50%); Duration of exposure:; - Level 1 (never exposed); - Level 2 (<7 years); - Level 3 (7 to 20 years); - Level 4 (>20 years); Cumulative exposure:; - Level 1 (never exposed); - Level 2 (low, <0.02); - Level 3 (medium, 0.02 to 0.09); - Level 4 (high, >0.09); Subjects with a probability of exposure >10%; Exposure to formaldehyde:; - Level 1 (never exposed); - Level 2 (ever exposed); Duration of exposure:; - Level 1 (never exposed); - Level 2 (≤7 years); - Level 3 (7 to 20 years); - Level 4 (>20 years); Cumulative exposure:; - Level 1 (never exposed); - Level 2 (low); - Level 3 (medium); - Level 4 (high); Other exposures:[underlined: asbestos], coal dust, leather dust, [underlined: wood dust], flour dust, silica, and textile dust.; [[underlined: As noted in] Appendix B.3.9: Of these, none significantly increased the risk of laryngeal cancer in this study but coal dust was controlled for in the laryngeal cancer analysis.] | Internal comparisons:; All subjects; [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.14 (0.76–1.70) | [102]
| | [underlined: Probability of exposure:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.16 (0.73–1.86) | [58]
| | Level 3 | OR = 1.12 (0.55–2.30) | [23]
| | Level 4 | OR = 1.04 (0.44–2.47) | [21]
| | [underlined: Cumulative exposure:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.12 (0.62–2.01) | [35]
| | Level 3 | OR = 1.44 (0.79–2.63) | [38]
| | Level 4 | OR = 0.87 (0.45–1.67) | [29]
| | [underlined: Duration of exposure:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.42 (0.75–2.68) | [35]
| | Level 3 | OR = 1.09 (0.62–1.96) | [37]
| | Level 4 | OR = 0.96 (0.52–1.76) | [30]
| | Subjects with a probability of exposure >10%; [underlined: Exposure to formaldehyde:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.17 (0.63–2.17) | [44]
| | [underlined: Cumulative exposure:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 0.68 (0.12–3.90) | [4]
| | Level 3 | OR = 1.86 (0.76–4.55) | [17]
| | Level 4 | OR = 0.91 (0.42–1.99) | [23]
| | [underlined: Duration of exposure:]
| | Level 1 | OR = 1.00 (Ref. value) | [194]
| | Level 2 | OR = 1.68 (0.60–4.72) | [15]
| | Level 3 | OR = 0.86 (0.33–2.24) | [14]
| | Level 4 | OR = 1.14 (0.47–2.74) | [15]
| | Introduction of induction times as described did not substantially change the results.
Reference: Wortley et al. (1992); Population: Males and females between the ages of 20 and 74 years residing in western Washington who were diagnosed with laryngeal cancer between September 1983 and February 1987 and identified through the cancer surveillance system of the Fred Hutchinson Cancer Research Center. Interviews completed for 80.8% of eligible cases and 80% of eligible controls.; Outcome definition: Diagnosis of cancer of the larynx based on ICD codes 161.0–161.9 from cancer registry data.; Design: Population-based case-control study of 235 cases of laryngeal cancer. 547 controls identified from random digit dialing and were selected for the same distributions of age and sex to the cases.; Analysis: ORs were calculated by multiple logistic regression and adjusted for smoking, drinking, age, and education. An induction period of 10 years was also utilized to account for latency in evaluating duration and exposure score.; [underlined: Confidence in effect estimates:]^a^ MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. | Exposure assessment: Occupational history obtained by interview for all jobs held for ≥6 months and included job titles, description of tasks performed, and industry. Job titles analyzed by duration of exposure (≤9 year and ≥10 years).; Exposures assessment based on job-exposure matrix. Industrial hygienists classified jobs into four levels of exposure to formaldehyde based on judgment of both likelihood and degree of exposure.; Exposure score calculated as the weighted sum of years with exposure, with weight based on level of exposure code. Exposure codes defined as: 0 = no, 1 = low, 2 = medium, and 3 = high.; Multiple exposure metrics including peak exposure (subject’s highest exposure code) and exposure score were evaluated.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Peak exposure:; - Level 1 (none); - Level 2 (low); - Level 3 (medium); - Level 4 (high); Duration:; - Level 1 (<1 years); - Level 2 (1 to 9 years); - Level 3 (≥10 years); Exposure scores:; - Level 1 (<5); - Level 2 (5 to 19); - Level 3 (≥20); Peak and Duration:; - Level 1 (none); - Level 2 (med/high and ≥10 years); - Level 3 (high and ≥10 years); Other exposures:[underlined: asbestos], [underlined: chromium], [underlined: nickel], cutting oils, and diesel fumes. High-risk occupations (e.g., mechanics, carpenters, painters, textile machine operators) likely had coexposures to unidentified substances.; [[underlined: As noted in] Appendix B.3.9: This is a case-control study the correlation between formaldehyde and those potential confounders is expected to be small, and thus, wood dust would not be expected to be a confounder.] | Internal comparisons:; [underlined: Peak exposure:]
| | Level 1 | OR = 1.0 (Ref. value) | [177]
| | Level 2 | OR = 1.0 (0.6–1.7) | [42]
| | Level 3 | OR = 1.0 (0.4–2.1) | [14]
| | Level 4 | OR = 2.0 (0.2–20) | [2]
| | [underlined: Duration:]
| | Level 1 | OR = 1.0 (Ref. value) | [182]
| | Level 2 | OR = 0.8 (0.4–1.3) | [27]
| | Level 3 | OR = 1.3 (0.6–3.1) | [26]
| | [underlined: Exposure scores:]
| | Level 1 | OR = 1.0 (Ref. value) | [201]
| | Level 2 | OR = 1.0 (0.5–2.0) | [18]
| | Level 3 | OR = 1.3 (0.5–3.3) | [16]
| | [underlined: Peak and Duration]
| | Level 1 | OR = 1.0 (Ref. value) [177]
| | Level 2 | OR = 4.2 (0.9–19.4) [not given]
| | [underlined: Peak and Duration]
| | Level 1 | OR = 1.0 (Ref. value) [177]
| | Level 2 | OR = 4.2 (0.9–19.4) [not given]
| | Level 3 | OR = 4.3 (1.0–18.7) [not given]
| | No notable findings were reported between formaldehyde exposure and the risk of laryngeal cancer when considering an induction period of 10 years.
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975–1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from laryngeal cancer (ICD-8: 161).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:]^a^ MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975–1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60–74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:
| | PMR = 0.64 (0.26–1.33) | | [7]
Reference: Meyers et al. (2013); Population: 11,043 workers in 3 U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion.; Outcome definition: Death certificates used to determine the underlying cause of death from laryngeal cancer (ICD code in use at time of death).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Pinkerton et al. (2004); Stayner et al. (1985); Stayner et al. (1988); [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984. Geometric TWA8 exposures ranged from 0.09 to 0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 to 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were not evaluated for this cancer.; Variation in exposure: Not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:
| | SMR = 0.77 (0.21–1.97) | | [4]
Reference: Gustavsson et al. (1998); Population: Males between the ages of 40 and 79 years residing in Sweden identified by hospitals reports or regional cancer registries during 1988–1990. Interviews completed for 90% of cases and 85% of controls.; Outcome definition: Diagnosis of laryngeal cancer based on ICD-9 codes on weekly reports from departments of otorhinolaryngology, oncology, and surgery and from regional cancer registries.; Design: Community-based, case-control study of 157 cases of squamous cell carcinoma of the larynx. 641 controls were randomly identified from population registers and frequency matched by region and age.; Analysis: RRs were calculated by unconditional logistic regression and adjusted for region, age, drinking, and smoking.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association.; Confounding possible.; Low sensitivity (exposure was rare). | Exposure assessment: Occupational history obtained by interview and yielded information on all jobs held >1 year, starting and stopping times, job title, tasks, and company. Histories reviewed by industrial hygienist who coded jobs based on intensity and probability of exposure to 17 occupational factors.; Exposure assessments estimated intensity on a 4-point scale and probability of exposure as point estimates. Cumulative exposure calculated as the product of exposure intensity, probability of exposure, and duration of exposure, and by adding contributions over entire work history.; Duration and timing: Duration of exposure was evaluated.; Variation in exposure:; Exposure to formaldehyde:; - Level 1 (never); - Level 2 (ever); Other exposures: polycyclic aromatic hydrocarbons, asbestos, general dust, wood dust, quartz, metal dust, oil mist, welding fumes, manmade mineral fibers, paper dust, textile dust, hexavalent chromium, phenoxy acids, nickel, acid mist, and leather dust.; [[underlined: As noted in] Appendix B.3.9: Asbestos and metal dust were both stronger risk factors for laryngeal cancer so there is a potential for confounding.] | Internal comparisons:; [underlined: Exposure to formaldehyde:]
| | Level 1 RR = 1.00 (Ref. value) [# not given]
| | Level 2 | RR = 1.45 (0.83–2.51) | [23]
Reference: Band et al. (1997); Population: 30,157 male workers in the pulp and paper industry with at least 1-year employment accrued by January 1950. Followed through December 1982. Loss to follow-up was less than 6.5% for workers exposed to the sulfate process (67% of original cohort of 30,157) and less than 20% for workers exposed to the sulfite process.; Outcome definition: Cause of death obtained from the National Mortality Database based on ICD version in effect at time of death and standardize to ICD-9 version. Larynx: ICD-9 161.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the Canadian population.; [underlined: Confidence in effect estimates:]^a^ ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible. | Exposure assessment: Occupational data limited to hire and termination dates for all workers and type of chemical process of pulping (sulfate vs. sulfite). No job-specific data available. Presumed exposure to formaldehyde known to be used in the plant. Formaldehyde is known to be an exposure risk for pulp and paper mill workers: job-specific median exposures ranging from 0.04 to 0.4 ppm with peaks as high as 50 ppm (Korhonen et al., 2004).; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure:; No variation in formaldehyde exposure was reported. Results presented by pulping process (sulfate vs. sulfite) but neither process uses formaldehyde which is used in paper making.; Coexposures: Not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9: Potential confounders for these outcomes include chlorophenols, acid mists, [underlined: dioxin], and [underlined: perchloroethylene] and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:; [underlined: All workers]
| | SMR = 1.01 (90% CI 0.58–1.63) | | [12]
| | Workers only in sulfite process; All workers
| | SMR = 1.78 (90% CI 0.78–3.52) | | [8]
| | Work duration <15 years
| | TSFE <15 years
| | SMR = 2.46 (90% CI 0.10–11.63) | | [1]
| | TSFE ≥15 years
| | SMR = 2.13 (90% CI 0.72–4.87) | | [4]
| | Work duration ≥15 years
| | TSFE ≥15 years
| | SMR = 0.93(90% CI 0.04–4.38) | | [1]
Reference: Jakobsson et al. (1997); Population: 727 male employees of two plants producing stainless steel sinks and saucepans employed at least 1 year during 1927–1981 with minimum 15-year follow-up.; Outcome definition: Incidence of laryngeal cancer from the Swedish Tumor Registry (ICD-7:161).; Design: Cohort incidence study with external comparison group.; Analysis: SIRs calculated using sex, age, and calendar-year-expected number of cases from the national population.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); High potential for information bias with attenuation of association (Exposure Group D). Confounding possible. Low sensitivity (few cases). | Exposure assessment: Workers grind stainless steel with grinding plates made of formaldehyde resins, which may release formaldehyde when heated during grinding operations.; Duration and timing: Occupational exposure preceding death during 1927–1981. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9: [underlined: Nickel] and [underlined: chromium] are associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other coexposures are not known risk factors for these outcomes.] | External comparisons:
| | SIR = 0.7 (0–3.9) | | [1]
Reference: Andjelkovich et al. (1995); Population: 3,929 automotive industry iron foundry workers exposed from 1960 to 1987 and followed through 1989.; Outcome definition: Underlying cause of death obtained from Social Security Administration, Pension Benefit Informations, and National Death Index); Larynx: ICD 161; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex-, age-, race-, and calendar-year-specific U.S. mortality rates.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Confounding possible for URT cancers. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure status (Yes/No, Quartile) base on review of work histories by an industrial hygienist.; Exposure assessment blinded to outcome.; Independent testing of iron foundries by NIOSH reported a range from 0.02 ppm to 18.3 ppm (cited in IPCS (1989) Env. Health Criteria 89: Formaldehyde).; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: [underlined: Nickel] and [underlined: chromium] are associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other coexposures are not known risk factors for these outcomes.] | External comparisons:
| | SMR_Unexposed_ = 0.70 (0.01–3.91) | | [1]
| | SMR_Exposed_ = 0.98 (0.11–3.53) | | [2]
Reference: Hansen and Olsen (1995); Population: 2,041 men with cancer who were diagnosed during 1970–1984 and whose longest work experience occurred at least 10 years before cancer diagnosis. Identified from the Danish Cancer Registry and matched with the Danish Supplementary Pension Fund.; Outcome definition: Cancer of the larynx (ICD-7: 161) listed on Danish Cancer Registry file.; Design: Proportionate incidence study with external comparison group.; Analysis: Standardized proportionate incidence ratio calculated as the proportion of cases for a given cancer in formaldehyde-associated companies relative to the proportion of cases for the same cancer among all employees in Denmark. Adjusted for age and calendar time.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity for NPC (few cases). | Exposure assessment: Individual occupational histories including industry and job title established through company tax records to the national Danish Product Register.; Subjects whose longest work experience was ≥10 years prior to cancer diagnosis were considered potentially exposed to formaldehyde. All subjects were stratified based on job title as either low exposure (white collar worker), above background exposure (blue collar worker), or unknown (job title unavailable).; Duration and timing: Exposure period since 1964.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: While other coexposures were not evaluated, the overall correlation between coexposures in multiple occupational industries is likely to be low.] | Overall (exposure to formaldehyde ≥10 years prior to cancer diagnosis)
| | SPIR = 0.9 (0.6–1.2) | | [32]
Reference: Stroup et al. (1986); Population: 2,239 white male members of the American Association of Anatomists from 1888 to 1969 who died during 1925–1979. Death certificates obtained for 91% with 9% lost to follow-up.; Outcome definition: Laryngeal cancer (ICD-8: 161) listed as cause of death on death certificates.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); High potential for selection bias. Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Confounding possible for ML. Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1925–1979. Median birth year was 1912. By 1979, 33% of anatomists had died. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:
| | SMR = 0.4 (0–2.0) | | [1]
Reference: Levine et al. (1984a); Population: 1,477 male undertakers licensed with the Ontario Board of Funeral Services from 1928 to 1957 who died during 1950–1977. Vital status was followed through 1977 with 96% completion and only 4% lost to follow-up.; Outcome definition: Death certificates used to determine cause of death from cancer of the larynx (ICD-8: 161).; Design: Retrospective cohort mortality study with external comparison group.; Analysis: Ontario mortality rates for <1950 not available for SMR calculations. Expected deaths were determined by applying age- and calendar year-specific mortality rates of Ontario men to the 1950 through 1977 experience of the cohort.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1950–1977. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:
| | Observed: 1
| | Expected: 1.0
| | SMR = 1.00 (0.05–4.93)^†^ | | [1]
| | ^†^EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1984); Population: 1,007 deceased white male embalmers from the California Bureau of Funeral Directing and Embalming who died during 1925–1980. Death certificates obtained for all.; Outcome definition: Laryngeal cancer listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1916–1978. Birth year ranged from 1847 to 1959. Median age of death was 62 years. Most deaths were among embalmers with active licenses. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene, xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:
| | Observed: 2
| | Expected: 2.6
| | PMR = 0.77 (0.13–2.54)^†^ | | [2]
| | ^†^EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1983); Population: 1,132 deceased white male embalmers licensed to practice during 1902–1980 in New York who died during 1925–1980 identified from registration files. Death certificates obtained for 75% of potential study subjects (n = 1,678).; Outcome definition: Laryngeal cancer listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:]^a^ LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing:; Occupational exposure preceding death during 1902–1980. Median year of birth was 1901. Median year of initial license was 1931. Median age at death was 1968. Expected median duration of exposure was 37 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, stains, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene is not associated with URT cancer.] | External comparisons:
| | Observed: 2
| | Expected: 3.4
| | PMR = 0.50 (0.10–1.94)^†^ | | [2]
| | ^†^EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

#### Respiratory Tract Cancers in Animal Studies

This section describes histopathological evidence reporting the induction of carcinomas, other neoplasms, and dysplasia in the respiratory tract of experimental animals after formaldehyde exposure. The discussion emphasizes observations of malignant tumors (e.g., adenocarcinomas and carcinomas and squamous cell carcinomas (SCCs), which were those most commonly observed) as representing the most advanced stage of rodent tumor malignancy. Other neoplasms were reported in the database, including adenomas and papillomas. While these neoplasms also represent abnormal changes to the respiratory tissue, the use of benign lesions to characterize potential human cancer risk is more straightforward when chemical-specific data are available to associate such lesions with the development of more malignant lesions along relevant progression pathways. For example, while squamous cell papillomas are benign lesions that could progress to become malignant SCCs in various rodent tissues, this progression through a benign papillomatous stage may not occur in rat nasal passages, whereas SCCs may arise directly from hyperplastic or dysplastic tissue (McConnell et al., 1986). Conversely, nasal polypoid adenomas (representing a different cellular lineage from those developing into SCCs) may progress to adenocarcinomas, which represent the more advanced stage in this cancer continuum. While benign and malignant rodent tumors are considered neoplasms, dysplasia is an example of a dedicated, preneoplastic lesion which may progress to neoplasia, and is therefore informative to the potential for human carcinogenesis. However, dysplasia itself is not cancer per se, but simply one possible stage along the presumed continuum of progressive changes characteristic of epithelial carcinogenesis. Thus, this section prioritizes discussion of incidence data for malignant tumors, representing the most advanced and rare lesions relevant to informing human cancer hazard; discussion of other neoplasms or dysplasia is presented separately, as supporting evidence.

This section describes the incidence, location, and severity of these lesions. Although, generally, the study authors cited in this section did not provide statistical comparisons for the reported lesions data, given the rarity of these neoplasms in unexposed animals (SCCs in particular), any observations of malignant tumors in the respiratory tract are considered to be biologically relevant, abnormal changes. Potential relationships between lesions or the potential for progression of benign lesions to malignant tumors are presented in the MOA discussion that follows. Other respiratory tract lesions that may be relevant to cancer development include hyperplasia and squamous metaplasia, which were discussed in Section 3.2.4.

Considering the long duration necessary for the development of these cancers, the evidence tables of the experimental animal studies are organized by study duration, specifically focusing on chronic exposure (≥1 year) and subchronic exposure (≥3 months) with long-term follow-up (typically assessed after ≥1 year). These studies are further organized by study confidence and species in Table 3-36. This section focuses on studies of high and medium confidence. Studies interpreted with low confidence for these endpoints are briefly summarized but excluded from the evidence tables. This includes all low confidence subchronic exposure studies that did not include a follow-up period to allow for the development of respiratory tract cancers, as described above (Zwart et al., 1988; Woutersen et al., 1987; Wilmer et al., 1989; Rusch et al., 1983; Maronpot et al., 1986; Andersen et al., 2010). The studies classified as not informative are not discussed (Horton et al., 1963; Coon et al., 1970; Casanova et al., 1994; Arican et al., 2009). A single, low confidence shorter-term (8 week) exposure study with less follow-up (32 week) is also discussed, as it was conducted in potentially sensitive mice (Morgan et al., 2017).

Animal studies investigating formaldehyde-induced respiratory carcinogenesis were carried out primarily in rats and to a lesser extent in mice, hamsters, and nonhuman primates. While the most consistent evidence of formaldehyde-induced respiratory cancers in animals is restricted to the nasal cavity and consists primarily of squamous cell carcinomas (SCCs), other neoplasms that have been observed include carcinomas other than SCCs, sarcomas, papillomas, and adenomas (Sellakumar et al., 1985; Morgan et al., 1986b; Monticello et al., 1996; Kerns et al., 1983; Kamata et al., 1997). Nasal tumors are rare in both mice and rats (Brown, 1990), thus any consistent increase in incidence is notable. Although dysplastic lesions, as well as hyperplasia and squamous metaplasia (see Section 3.2.4), have been observed posterior to the nasal cavity, respiratory tract tumors in these regions have not been reported to be significantly increased by formaldehyde treatment. In chronic studies in rats, carcinogenic effects generally first occur around 12 months in high exposure groups, with increased tumor incidence and decreased latency correlating with increasing exposure concentrations. Two medium confidence subchronic studies in rats with an extended period of observation also reported an increase in tumor incidence (Woutersen et al., 1989; Feron et al., 1988).

Although the bioassays in mice, hamsters, and rats represent similar exposure concentrations and duration of exposure, clear species differences in the severity of lesions are present. Hamsters display little histopathological change whereas rats exhibit gross toxicity and even increased mortality. Mice exhibit a range of effects on the respiratory epithelium, but not to the severity observed in rats. There are significant species differences in the anatomical structure of the airways, and in oral/nasal breathing patterns, including reflex bradypnea (see Appendix C.2 for discussion), all of which may influence areas of formaldehyde absorption or flux into the tissue. The differential toxicity of formaldehyde on the URT in animals may also be due to localized differences in mucus flow and production, as well as differences in the expression or distribution of enzymes involved in formaldehyde detoxification. Overall, as discussed below, inhalation exposure to formaldehyde in experimental animals induces nasal cancer and dysplasia with increasing incidence as a function of exposure duration and concentration at the POE.

##### Squamous cell carcinomas

Squamous cell carcinomas (SCCs) are the most consistently observed respiratory tract cancer in mice and rats exposed to formaldehyde. These malignant tumors likely arise from squamous cells, a type of differentiated epithelial cell that also comprises the majority of the epidermis (“skin” cells). Formaldehyde-induced SCCs are restricted to the nasal cavity and have not been observed in any other region of the respiratory tract. The most useful and abundant SCC data (i.e., the large majority of studies interpreted with medium or high confidence) are from studies of exposed rats. Following exposure of rats to formaldehyde for 2 years, an increase in SCCs was observed in 5 of 6 studies (see Table 3-36 and Figure 3-23). These tumors were detected in exposed male and female Fischer 344 (F344) and Sprague Dawley rats, but findings in Wistar rats were less clear (see discussion below). Overall, SCCs were not reproducibly detected below 6 mg/m^3^ formaldehyde in rats; however, none of the available rat studies tested exposure between 3 and 6 mg/m^3^, introducing uncertainty. Reflecting the rarity of these tumors [rat background incidence averages <0.3% (Brown et al., 1991)], the incidence in control groups across the chronic formaldehyde exposure studies in rats was 0%. Generally, the incidence increased to around 1% at approximately 7 mg/m^3^ formaldehyde, and further increased to around 40% as formaldehyde concentrations neared 18 mg/m^3^ (Note that for purpose of comparison across studies, Table 3-36 reports incidence rates unadjusted for mortality; see Section 5.2.1 for mortality-adjusted rates. Unadjusted rates are generally underestimates; for example, the adjusted cumulative incidence rate in female rats exposed for 24 months at 17.6 mg/m^3^ by Kerns et al. (1983) was reported at 87%).

The data as reported in Kerns et al. (1983) and Monticello et al. (1996) were corrected in a memorandum issued by the CIIT Centers for Health Research, which had sponsored or conducted these studies (Bermudez, 2004). The corrected data are noted in separate rows in Table 3-36. The correction for Kerns et al. (1983) in the CIIT memo (2004 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=4164544)) indicates the number of animals examined instead of the number of animals in the experiment. The corrections for Monticello et al. (1996) issued in the CIIT memo (2004 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=4164544)) arise from an examination by CIIT scientists of tissues for an additional group of 94 rats from the study that had not been previously examined (as explained in(Conolly et al., 2003)).^30^ These tissues were from the 12-, 18-, and 24-month time points and were distributed approximately evenly across the six exposure concentrations. The CIIT memo (Bermudez, 2004) is reproduced in the Appendix D.2.2.

Table 3-36 Squamous cell carcinoma (SCC) incidence in rats^a^ exposed to formaldehyde for ≥2 years

| Strain | Sex | Formaldehyde concentration range^b^ (specific mg/m^3^ examined)
| Strain | Sex | 0 | 0 < × < 3 | 3 < × < 6 | 6 < × < 9 | 9 < × < 12 | 12 < × < 15 | 15 > × > 18.5
High confidence
Kerns et al. (1983) | F344 | M | 0/118 | 0/118 (2.5^c^) | — | 1/119 (6.9) | — | — | 51/117 (17.6)
Kerns et al. (1983) | F344 | F | 0/114 | 0/118 (2.5) | — | 1/116 (6.9) | — | — | 52/115 (17.6)
Corrected Bermudez (2004) | | M and F | 0/237 | 0/239 | — | 2/235 | — | — | 83/225
Monticello et al. (1996) | F344 | M | 0/90 | 0/90 (0.9); 0/90 (2.5) | — | 1/90 (7.4) | — | 20/90 (12.2) | 69/147 (18.4)
Corrected Bermudez (2004) | | M and F | 0/104 | 0/221 | — | 1/108 | | 22/103 | 79/161
Woutersen et al. (1989) | Wistar | M | 0/26 | 1/26 (0.1); 1/28 (1.2) | — | — | — | 1/26 (12.1) | —
Medium confidence
Holmstrom et al. (1989b) | Sprague Dawley | F | 0/15 | — | — | — | — | — | 1/16 (15.3)
Kamata et al. (1997) | F344 | M | 0/32 | 0/32 (0.4); 0/32 (2.7) | — | — | — | — | 13/32 (18.3)
Sellakumar et al. (1985) | Sprague Dawley | M | 0/99 | — | — | — | — | — | 38/100 (18.2)
Formaldehyde range (mg/m^3^) | | | 0 | 0 < × < 3 | 3 < × < 6 | 6 < × < 9 | 9 < × < 12 | 12 < × < 15 | 15 > × > 18.5
Total rats examined Range of percentage incidence^d^/study | | | 494; 0–0% | 534; 0–3.8%^e^ | 0; — | 325; 0.8–1.1% | 0; — | 116; 3.8–22.2% | 527; 6.3–46.9%

F344: Fischer 344; M: Male; F: Female; — Concentrations in this range were not examined.

a This table is restricted to experimental studies in rats, given toxicokinetic differences across species. A mouse (Kerns et al., 1983) and hamster (Dalbey, 1982) study also meet confidence and exposure duration criteria.

b These ranges were arbitrarily chosen to cover the available data and do not have a biological basis.

c The specific concentration(s) of formaldehyde tested in the study is in parentheses.

d Incidence rates are unadjusted for mortality.

e Both SCCs in this concentration range are from Woutersen et al. (1989), which did not observe any increases in SCCs at much higher formaldehyde concentrations in Wistar rats, reducing confidence in these findings.

Figure 3-23 Nasal SCCs in rats exposed to formaldehyde for at least 2 years

Incidence data for squamous cell carcinomas from the high and medium (unfilled shapes) confidence studies evaluating formaldehyde exposures of at least 2 years.

The data suggest that rats of different strains may vary in their sensitivity to formaldehyde-induced SCCs. The only rat study with 2 years of formaldehyde exposure that did not observe an association of SCCs with increasing formaldehyde exposure was conducted in Wistar rats (Woutersen et al., 1989). Although the authors reported a single SCC in each of the treatment groups (no SCCs were observed in controls), these tumors may not have been related to formaldehyde exposure as the incidence did not change at higher formaldehyde levels and observations of SCCs occurred at far lower concentrations than in any other rat studies. Consistent with this potential resistance of Wistar rats to formaldehyde-induced SCCs observed by Woutersen et al. (1989), an earlier study from the same laboratory examining Wistar rats at identical formaldehyde concentrations did not detect any SCCs (Appelman et al., 1988); however, the earlier study only exposed and observed animals for 12 months, substantially reducing its ability to detect cancers. Two additional experiments from the same laboratory examined whether subchronic formaldehyde exposure with follow-up for more than 2 years resulted in SCCs in Wistar rats (Woutersen et al., 1989; Feron et al., 1988). Both of these studies observed a single SCC induced in response to formaldehyde exposure at approximately 11 mg/m^3^, with an increased incidence of formaldehyde-induced SCCs to 3 of 44 in the study that tested a higher exposure of 24.4 mg/m^3^ (Feron et al., 1988). The <4% incidence in Wistar rats exposed to approximately 11 mg/m^3^ in these studies contrasts with the 22% incidence observed at this level in F344 rats by Monticello et al. (1996). Taken together, although some of the data with a sufficient duration of observation suggest that formaldehyde exposure can induce a low incidence of SCCs in Wistar rats (Woutersen et al., 1989; Feron et al., 1988), these findings indicate that this strain may be resistant to formaldehyde-induced nasal SCCs, as compared to F344 and Sprague Dawley rats.

The effects of long-term formaldehyde exposure in species other than rats are less well studied, but the available data suggest that rats may be the most sensitive laboratory rodents. The only mouse study testing exposure of at least 2 years (Kerns et al., 1983) provided support for the consistent observations of SCCs in formaldehyde-exposed rats. In this well-conducted (i.e., high confidence) study, SCCs were observed at 17.6 mg/m^3^, but not at 6.9 or 2.5 mg/m^3^ (incidence in controls was 0%). The incidence at 17.6 mg/m^3^ was <2% (2/120), in contrast with the >40% incidence detected in F344 rats exposed to similar formaldehyde concentrations by the same study authors (Kerns et al., 1983). The authors also reported that the SCCs in rats were more invasive and severe than those observed in mice. These differences could reflect the use of a mouse strain that might be insensitive to these effects, similar to the above discussion of Wistar rats, but the differences more likely reflect a decreased response due to a lower inhaled dose of formaldehyde resulting from differences in breathing patterns and irritant responses across species (see Appendices A2 and A3). In contrast, no respiratory tract tumors were observed in Syrian golden hamsters exposed to 12.3 mg/m^3^ of formaldehyde for a lifetime (Dalbey, 1982), although no other exposure levels were tested to inform whether this species or strain may also be less sensitive than exposed F344 and Sprague Dawley rats, and exposed mice.

In rats and mice, SCC formation appears to be dependent on both the formaldehyde concentration and the duration of exposure and observation. Specifically, higher formaldehyde exposure levels tend to be associated with both an increased incidence and an earlier onset of tumor formation. An example of this was demonstrated in a follow-up to the Kerns et al. (1983) study by Monticello et al. (1996). Monticello et al. (1996) reported that the incidence of SCCs in rats exposed to 18.4 mg/m^3^ formaldehyde was 47%, with the first tumor noted at 12 months. The incidence of SCCs in the 12.2 mg/m^3^ exposure group was lower, at 22%, and the tumor latency was longer, with the first SCC observed at 18 months. Of the 90 rats exposed at 7.4 mg/m^3^ for 20 months, only one SCC was noted, and no SCCs were detected at 0, 0.85, or 2.52 mg/m^3^ over 28 months (Monticello et al., 1996). Initial observations of SCCs varied across the available rat studies, and the study design sometimes prevented an accurate determination of the timing (e.g., microscopic examinations may have been conducted every 6 months, every year, or only after 2 years). However, the first tumor generally was not observed before 12 months of observation, and often took 16 months or longer to develop (see Table 3-37). Consistent with this long latency, SCCs observed in mice took 2 years to develop (Kerns et al., 1983), and no URT neoplasms were observed during 8 months of observation in a short-term, low confidence (i.e., due to its 8-week exposure duration and <1 year follow-up) study of potentially sensitive mice (Morgan et al., 2017). In light of these observations, subchronic and shorter-term exposure studies without a long duration of follow-up are not expected to be capable of detecting formaldehyde-induced SCCs^31^. In studies where interim sacrifices were performed and described, longer durations of exposure were generally associated with an increased incidence, severity, and sometimes more posterior location, of the induced SCCs (Monticello et al., 1996; Kerns et al., 1983). These data suggest that longer formaldehyde exposure duration is correlated with a greater incidence and severity of SCCs.^32^

The large bioassay of Kerns et al. (1983) in F344 rats showed no overt differences in the development of SCCs across sexes (i.e., 51/117 in males vs. 52/117 in females at 17.6 mg/m^3^). There is some evidence to suggest that male rodents may be more sensitive to these effects. For example, only 1 of 16 female Sprague Dawley rats exposed to 15.3 mg/m^3^ developed SCCs (Holmstrom et al., 1989b), whereas slightly higher levels (18.2 mg/m^3^) of formaldehyde in another study of male Sprague Dawley rats (Sellakumar et al., 1985) induced more than six times as many SCCs (38/100). In addition, only male mice (2/120), but not female mice (0/120), developed SCCs in a chronic study (Kerns et al., 1983). However, these suggestions of differential sensitivity between sexes are not easily interpreted given the small sample sizes (Holmstrom et al., 1989b) and a low incidence of SCCs in exposed mice (Kerns et al., 1983).

The locations of the induced SCCs were consistent with both the distribution of inhaled formaldehyde and locations of other formaldehyde-induced nasal pathologies (see Section 3.2.4), with SCCs arising from the epithelium lining the airway and not from the underlying glandular epithelium. These tumors were most commonly observed in anterior regions of the nasal cavity, although higher exposure levels sometimes resulted in progression of SCCs to more posterior locations. Morgan et al. (1986b) mapped the location of formaldehyde-induced SCCs from the Kerns et al. (1983) study. In F344 rats, the majority of animals had single tumors, with a little under 20% of each sex with tumors developing multiple neoplasms. More than half (57%) of the SCCs occurred on the lateral side of the nasoturbinate and adjacent lateral wall at the front of the nose (Levels I and II; see Table 3-37); approximately 25% were located on the midventral nasal septum (Levels II and III); and about 10% were on the dorsal septum and roof of the dorsal meatus (Levels I, II, and III). A small number (3%) were found on the maxilloturbinate (Levels II and III), which only involved the medial aspect. Similar observations were reported for other studies of F344 rats (Monticello et al., 1996) and B6C3F1 mice (Kerns et al., 1983). Locations of SCCs in Sprague Dawley and Wistar rats were not as specifically reported in the available studies, but were generally similar, primarily affecting the respiratory epithelium lining the septum and nasoturbinates (Woutersen et al., 1989; Sellakumar et al., 1985).

##### Other malignant neoplasms

Although the data on other neoplasms are far less robust than those related to SCCs, formaldehyde inhalation also appears to induce other types of malignant nasal tumors. The incidence of these other neoplasms was typically only one, or rarely two, animals in an exposed group (never in controls); however, it is considered highly unlikely that these are incidental, as these rare neoplasms only developed after exposure to the highest formaldehyde concentrations, typically those above 17 mg/m^3^ (see Table 3-37). As with SCCs, these neoplasms were limited to the nasal cavity. Carcinomas, which derive from epithelial tissues, were reported in several studies with an observation period greater than 2 years, consistent with the pronounced effect of inhaled formaldehyde on the nasal epithelium. A single nasal carcinoma was observed in both male and female F344 rats (Kerns et al., 1983), a mixed carcinoma was observed in male Sprague Dawley rats (Sellakumar et al., 1985), and a carcinoma in situ was observed in male Wistar rats exposed to 24 mg/m^3^ (Feron et al., 1988), but not ≤12.1 mg/m^3^ (Woutersen et al., 1989; Feron et al., 1988; Appelman et al., 1988).

##### Nonmalignant neoplasms

Several other benign tumors of the respiratory tract have been reported following formaldehyde exposure in rats, but not in other species. These tumors parallel findings for the other observed tumors, in that they are restricted to the nasal cavity and generally take more than 12 months to develop. Overall, these tumors appear to represent an erratic growth of the nasal epithelial tissue (i.e., adenomas and papillomas), with the exception being an ameloblastoma observed at 24 mg/m^3^ formaldehyde (Feron et al., 1988), a tumor that presumably secondarily infiltrated the nasal cavity. In male Sprague Dawley rats, 10% of animals (10/100) exposed to 18.2 mg/m^3^ for their lifetime developed nasal polyps or papillomas (Sellakumar et al., 1985; Albert et al., 1982), while approximately the same percentage of male F344 rats (3/32) exposed to a near-identical formaldehyde concentration (18.3 mg/m^3^) developed squamous cell papillomas (Kamata et al., 1997). Polypoid adenomas have also been consistently observed in response to formaldehyde exposure. Similar to SCCs, and in contrast to the other malignant tumors discussed above, these neoplasms may be inducible at formaldehyde concentrations below 12 mg/m^3^, and perhaps even below 7 mg/m^3^, although the data are somewhat more variable as compared to the SCC data (see Table 3-37). Polypoid adenomas were increased compared to controls in male Wistar rats exposed to 11.3 mg/m^3^ (Woutersen et al., 1989) or 24.2 mg/m^3^ (Feron et al., 1988) for 3 months with follow-up to >2 years, and in chronically exposed F344 rats (Monticello et al., 1996; Kerns et al., 1983). The responses in F344 rats occurred primarily in males and were reported at concentrations as low as 2.5 mg/m^3^ (Kerns et al., 1983), although interpretation of the incidence data across exposure levels is not straightforward. Taken together, the data indicate that benign epithelial tumors in the nasal cavity can be induced by formaldehyde exposure.

##### Dysplasia

Similar to observations of nasal tumors, the incidence of dysplasia in long-term formaldehyde inhalation studies in rats and mice (i.e., chronic or subchronic exposure with observation periods of >12 months) increased in severity and occurred in more distal portions of the nasal cavity with both formaldehyde concentration and duration. Whereas the rat nasal tumor data consistently demonstrated that tumors are restricted to the nasal cavity, one study reported that F344 rats (which appear to be sensitive to these effects) also exhibited mild dysplasia in the trachea (Kerns et al., 1983), although the tracheal lesions were not observed when rats exposed for 2 years were left unexposed for 3 months. The study authors did not observe any tracheal lesions in mice (Kerns et al., 1983). Epithelial dysplasia of the nasal cavity was first noted at 12 months in rats exposed to concentrations as low as 2.5 mg/m^3^, and in a “few” mice after 18 or 24 months of exposure at concentrations as low as 6.9 mg/m^3^ formaldehyde (Kerns et al., 1983). However, after 24 months of exposure to 17.6 mg/m^3^ formaldehyde, the incidence of nasal dysplasia was significantly increased in rats and mice, with greater than 90% of mice exhibiting this lesion (Kerns et al., 1983). The study authors noted that the identification of dysplasia in this study may have been termed metaplasia or hyperplasia by other study authors (Kerns et al., 1983), suggesting that this may represent a sensitive estimate of dysplasia. In another study, a female Sprague Dawley rat exposed to 15.3 mg/m^3^ formaldehyde for a lifetime also developed dysplasia of the nasal epithelium (Holmstrom et al., 1989b). In line with the nasal tumor data, studies of Wistar rats and hamsters did not identify dysplastic lesions (see Table 3-37).

Table 3-37 Respiratory tract cancer—chronic and subchronic (with long-term follow up) exposure in rats, mice, and hamsters

Reference and study design^a^ | Results
Chronic exposure
High confidence
Rats
Monticello et al. (1996); Rats: F344; male; 90–147/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for up to 24 months at 0, 0.85, 2.52, 7.40, 12.2, or 18.4 mg/m^3^; Histopathology^b^: 6 sections of the nasal cavity | Malignant tumors in the nasal cavity^a^
| | | | 0, 0.85, or 2.52 mg/m^3^ | 7.4 mg/m^3^ | 12.2 mg/m^3^ | 18.4 mg/m^3^
| Squamous cell carcinoma^b^ | | | 0/90 | 1/90 (1%) | 20/90 (22%) | 69/147 (47%)
| Adenocarcinoma | | | 0/90 | 0/90 | 1/90 | 1/147
| Rhabdomyosarcoma | | | 0/90 | 0/90 | 1/90 | 1/147
| Other neoplasms
| Polypoid adenoma | | | 0/90 | 0/90 | 5/90 (6%) | 14/147 (10%)
| ^a^Spontaneous buccal SCCs were observed at 0, 2.52, and 18.4 mg/m^3^; ^b^SCCs that could be localized were identified most often in the anterior or posterior lateral meatus 1/90, 12/90, 17/147 or 0/90, 12/90, 9/147 corresponding to 7.4, 12.2, and 18.4 mg/m^3^); SCCs were also observed in the mid- and dorsal septum, as well as the maxilloturbinates, but only at 18.4 mg/m^3^; however, most tumors were too large to localize and these often eroded through nasal bone and invaded the subcutis of the dermis. Tumors began appearing ^~^1 year at 18.4 mg/m^3^ and ^~^1.5 year at 12.2 mg/m^3^; No tumors observed beyond the respiratory tract
Woutersen et al. (1989); Rats: Wistar; male; 30/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for 28 months at 0, 0.1, 1.2, or 12.1 mg/m^3^; Histopathology^b^: 6 nasal cross sections; Note: experiments with nasal damage prior to exposure are not presented here | Malignant tumors
| | | | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 12.1 mg/m^3^
| Squamous cell carcinoma | | | 0/26 | 1/26 | 1/28 | 1/26
| Adenosquamous carcinoma | | | 0/26 | 0/26 | 0/28 | 0/26
| Adenocarcinoma | | | 0/26 | 0/26 | 0/28 | 0/26
| Note: the specific locations of these tumors was not described
Sellakumar et al. (1985); Rats: Sprague Dawley; male; 99–100/group; Test article: Paraformaldehyde (slurry in paraffin oil); Exposure: 6 hr/d, 5 d/week for lifetime at 0 or 18.2 mg/m^3^ [Note: prior reporting of levels during first 588 days at 17.5 mg/m^3^ (Albert et al., 1982)]; Histopathology^b^: multiple (interpreted as ≥ 5 based on study description) sections of the head (from just behind the nostril to the eye orbits), lung, trachea, and larynx; Related study: Albert et al. (1982) | | | | | Colony Control | Air sham | 18.2 mg/m^3^
| Malignant tumors in the nasal mucosa
| Squamous cell carcinoma^a^ | | | | 0/100 | 0/99^b^ | 38/100
| Adenocarcinoma | | | | 0/100 | 0/99 | 0/100
| Mixed carcinoma | | | | 0/100 | 0/99 | 1/100
| Fibrosarcoma | | | | 0/100 | 0/99 | 1/100
| Other neoplasms in the nasal mucosa
| Polyp or papillomas | | | | 0/100 | 0/99 | 10/100
| ^a^Predominantly moderate/well differentiated, keratin obstructed lumen; latency to tumor formation was approximately 603–645 days; No tumors observed in the trachea or lungs
Kerns et al. (1983); Rats: F344; males and females; 119 to 121/sex/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for up to 2 year (recovery: 27 and 30 months) at 0, 2.5, 6.9, or 17.6 mg/m^3^; Histopathology^b^: 5 sections of nasal turbinates (Levels I–V) for animals that died or at interval sacrifices (i.e., at months 6, 12, 18, 24, 27, and 30); Related study/earlier reports: (Battelle, 1981, 1982); [interim findings presented in Swenberg et al. (1980b)]; Note: viral infection reported (sialodacryoadenitis) at approximately weeks 52–53 (Kerns et al., 1983); the authors attributed transient decreases in body weight to this infection. This infection was not interpreted to affect the reliability of the cancer incidence data, in part because dysplasia and other lesions were already present at 12 months (when the infection began) | Malignant tumors
| mg/m^3^ | | | 0 | 2.5 | 6.9 | 17.6
| Squamous cell carcinoma^a^
| Male | | | 0/118 | 0/118 | 1/119 | 51/117
| Female | | | 0/114 | 0/118 | 1/116 | 52/115
| Nasal carcinoma
| Male | | | 0/118 | 0/118 | 0/119 | 1/117^b^
| Female | | | 0/114 | 0/118 | 0/116 | 1/115
| Carcinosarcoma
| Male | | | 0/118 | 0/118 | 0/119 | 1/117
| Female | | | 0/114 | 0/118 | 0/116 | 0/115
| Undifferentiated carcinoma or sarcoma
| Male | | | 0/118 | 0/118 | 0/119 | 2/117^b^
| Female | | | 0/114 | 0/118 | 0/116 | 0/115
| Other Neoplasms
| Polypoid adenoma
| Male | | | 1/118 | 4/118 | 6/119 | 4/117
| Female | | | 0/114 | 4/118 | 0/116 | 1/115
| Epithelial Dysplasia
| 6 months | | | –^c^ | – | – | –^d^
| 12 months | | | –^c^ | Level I^e^ | Level I–III^f^ | Level I–V^f^
| 18 months | | | –^c^ | NR | Level I–III^f^ | Level I–V^f^
| 24 months | | | –^c^ | Level I | Level I–III^f^ | Level I–V^f^
| ^a^SCCs became clinically observable in females at ^~^12 months, and in males at ^~^14 months; most appeared to originate in the nasoturbinates; ^b^A rat in this group also had SCC; ^c^Lesion frequency (dysplasia or metaplasia) of <15% at 0 mg/m^3^ (Level I); ^d^ Although formaldehyde-induced lesions were identified in Level I–III, the authors did not specify them as dysplasia; ^e^Squamoid epithelial lining several cells thick with polarity changed from vertical to horizontal was noted and termed dysplasia, but authors acknowledged related changes can be termed hyperplasia or metaplasia; ^f^Dysplasia was most intense in Level I. Exposure-related effects were observed in Levels I–III and I–V at 6.9- and 17.6-mg/m^3^, respectively, although the specific timing for these lesions was not provided; note: dysplasia was consistently detected earlier than squamous metaplasia; Trachea: at 17.6 mg/m^3^, minimal-to-mild dysplasia at 18 months, with greater frequency (p < 0.05) in 24-month and unscheduled deaths groups; trachea lesions not observed in postexposure group or at lower levels
Mice
Kerns et al. (1983); Mice: B6C3F1; males and females; 119 to 121/sex/group; Exposure: 6 hr/d, 5 d/week for up to 24 months (recovery at 27 and 30 months) at 0, 2.5, 6.9, or 17.6 mg/m^3^; Test article: Paraformaldehyde; Histopathology^b^: 3 sections of nasal turbinates, defined as Levels II, III, and V for all animals that died or were sacrificed at scheduled intervals (i.e., at month 6, 12, 18, 24, 27, and 30); Earlier reports: Battelle (1981, 1982); Main limitations: Lesion incidence NR for dysplasia; only 3 nasal sections examined | Malignant tumors
| | | | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| SCCs at 24 months^a^ | | | 0/^~^120 (both sexes) | 0/^~^120 (both sexes) | 0/^~^120 (both sexes) | 2/^~^120 male; 0/^~^120 female
| Dysplasia^b^
| 12 months | | | – | – | – | –
| 18 months | | | – | – | Level II: “few” | Level II (^~^90%)
| 24 months | | | – | – | Level II: “few” | >90%
| Recovery (27 months) | | | – | – | none | yes (incidence and level NR)
| ^a^SCCs were not observed prior to 24 months (p > 0.05); both SCCs originated from nasoturbinates; the number of mice evaluated was not specified, but assumed ^~^120 based on 119–121 mice/group; ^b^Unless noted, exact frequency of lesion NR, and sex not specified; No tracheal lesions were observed
Medium confidence
Rats
Kamata et al. (1997); Rats: F344; male; 32/group; Test article: Formalin (methanol control); Exposure: nose-only 6 hr/d, 5 d/week for up to 28 months at 0, 0.40, 2.67, or 18.27 mg/m^3^ (methanol—0, 18.27 mg/m^3^ groups, estimated at 5.5 mg/m^3^, presumed from percentage methanol in formalin); Histopathology^b^: nasal region (sections from five anatomical levels) and trachea; Main limitations: small sample size; use of formalin (uncertainties, such as possible differences in tissue formaldehyde due to methanol, remain despite inclusion of a methanol control) | | Months (interim sac.) | | | | Dead | All
| | 12 | 18 | 24 | 28 | Dead | All
| Squamous cell carcinomas at 18.27 mg/m^3a^
| SCCs | 0/5 | 1/5 | 0/2 | 0/0 | 12/20 | 13/32^b^
| Other malignant tumors at 18.27 mg/m^3a^
| Unclassified sarcoma | 0/5 | 0/5 | 0/2 | 0/0 | 0/20 | 0/32
| Sarcoma | 0/5 | 0/5 | 0/2 | 0/0 | 1/20 | 1/32
| Other neoplasms at 18.27 mg/m^3a^
| Squamous cell papilloma | 0/5 | 1/5 | 0/2 | 0/0 | 2/20 | 3/32
| ^a^No nasal tumors were observed at 0, 0.4, or 2.67 mg/m^3^ (note: 1 unclassified sarcoma found in a dead room control group rat); average latency across groups varied from 603 and 645 days; ^b^Significant at p ≤ 0.01, compared with the 0 mg/m^3^ group.; Note: Most tumors were located in levels B and C (see diagram in left column); large tumors invaded the subcutis through the nasal bones
| No tumors were observed in the trachea
Holmstrom et al. (1989b); Rats: Sprague Dawley; female; 15–16/group Test articles: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for 104 weeks at 0 or 15.3 mg/m^3^; Histopathology^b^: 5 sections of the nose from the vestibulum to the posterior ethmoturbinatic region, and the lungs Note: data on wood dust combined with formaldehyde exposure not evaluated; Main limitations: Limited reporting; some health issues noted | Malignant tumors
| | | | Air control | | 15.3 mg/m^3^
| Squamous Cell Carcinoma | | | 0/15 | | 1/16^a^
| Dysplasia
| | | | 0/15 | | 1/16^b^
| ^a^Observed after 21 months after exposure; ^b^An addition two rats exhibited pronounced squamous metaplasia with keratinization (7 more exhibited squamous metaplasia)
| Note: Mortality was similar in both groups
Appelman et al. (1988); Rats: SPF Wistar; male; 10/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for 52 weeks at 0.12, 1.2, or 12.1 mg/m^3^; Histopathology^b^: nose (6 standard cross levels), larynx, trachea, and lungs; Note: experiments with nasal damage prior to exposure are not presented here; Main limitations: 1-year short duration to allow for cancer development | No dysplasia or nasal neoplasms were observed in nose, larynx, trachea, or lungs with exposure up to 12.1 mg/m^3^ for up to 1 year (assumed, based on histopathological evaluation of these tissues, although the study authors did not specifically state these conclusions)
Hamsters
Dalbey (1982); Hamsters: Syrian golden; male; 132 untreated controls and 88 exposed; Test article: Paraformaldehyde; Exposure: 5 hr/d, 5 d/week for a lifetime at 0 or 12.3 mg/m^3^; Histopathology^b^: Two transverse sections of the nasal turbinates, and sections of the larynx, trachea, and lungs; Main limitations: minimal sampling, histological evaluation, and reporting Note: mixture experiment not evaluated | No tumors reported in the nose, larynx, lungs, or trachea with a lifetime of exposure to 12.3 mg/m^3^; Note: study authors indicated formaldehyde exposure at 36.9 mg/m^3^ amplified diethylnitrosamine-induced respiratory tumors.
Subchronic exposure with long-term follow-up
High confidence
Rats
Woutersen et al. (1989); Rats: Wistar; male; 30/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for 3 months at 0, 0.1, 1.2, or 11.3 mg/m^3^; sacrificed at 28 months; Histopathology^b^: 6 nasal cross sections; Note: short duration of exposure | | | | 0 mg/m^3^ | 0.1 mg/m^3^ | 1.2 mg/m^3^ | 11.3 mg/m^3^
| Malignant tumors
| Squamous cell carcinoma | | | 0/26 | 0/30 | 0/29 | 1/26
| Carcinoma in situ | | | 0/26 | 0/30 | 0/29 | 0/26
| Other neoplasms
| Polypoid adenoma | | | 0/26 | 0/30 | 0/29 | 1/26
| Note: cross-section locations not specified
Medium confidence
Rats
Feron et al. (1988); Rats: Wistar; male; 45/group; Test article: Paraformaldehyde; Exposure: 6 hr/d, 5 d/week for up to 13 weeks at 0, 11.3–11.9, or 24.2–24.4 mg/m^3^; sacrificed at 130 weeks; Histopathology^b^: 6 standard cross levels of the nose.; Main limitations: Limited reporting; short duration of exposure | | | | | 0 mg/m^3^ | ^~^11.5 mg/m^3^ | ^~^24 mg/m^3^
| Malignant tumors
| Squamous cell carcinoma:
| 4-week exposure (week sacrificed indicated) | | | | 0/44 | 0/44 | 1/45 (week 106)
| 8-week exposure | | | | 2/45 (week 94, 130) | 1/44 (week 130) | 1/43 (week 121)
| 13-week exposure | | | | 0/45 | 1/44 (week 82) | 3 or 4/44^a^ (week 63, 112, 114, NR)
| Other malignant tumors with 13 week exposure^b^:
| Carcinoma in situ: | | | | 0/45 | 0/44 | 1/44 (week 81)
| Other neoplasms
| Ameloblastoma: | | | | 0/45 | 0/44 | 1/44 (week 73)
| Polypoid adenoma:
| 4 week exposure | | | | 0/44 | 0/44 | 1/45 (week 110)
| 8 week exposure | | | | 0/45 | 0/44 | 1/43 (week 100)
| 13 week exposure | | | | 0/45 | 0/44 | 0/44
| ^a^1 SCC was classified as a “cystic SCC,” which may have been derived from the palate, and which the authors did not associate with exposure; ^b^carcinomas other than SCC were not observed with <13 week exposure

Organized by study design, species, confidence, and then descending publication date.

Abbreviations: NR = not reported; F = Fischer; hr = hour(s); d = day(s); wk = week(s); yr = year(s).

a Analytical formaldehyde levels are presented and, unless otherwise noted, whole-body exposures were used.

b The studies used the same sectioning levels described for noncancer lesions in Section 3.2.4.

##### Summary of Animal Evidence Synthesis Judgments

The available animal studies on respiratory tract cancers provide robust evidence of formaldehyde exposure-induced nasal cancers. The locations of the observed cancers in animals are interpreted as most relevant to human NPC and sinonasal cancers. The following factors were most influential to the synthesis judgment.

- Consistency and Study Confidence: Tumors of the respiratory tract (predominantly nasal squamous cell carcinomas, SCCs, but including other epithelial and nonepithelial tumors) were consistently observed in mice and in several strains of rats in numerous high and medium confidence studies, but not in hamsters, generally at formaldehyde levels above 6 mg/m^3^. These lesions were never observed in other respiratory tract regions, such as the larynx and lung, and they generally only developed in animals that were observed for longer than 12 months.
- Dose-Response: The lesion incidence, as well as the tumor invasiveness and latency, was demonstrated to worsen with increasing formaldehyde exposure level. In addition, the development of these lesions, particularly the SCCs, depended on the duration of observation and, based on an increasing incidence and severity of lesions in animals exposed for longer periods of time, the formaldehyde exposure duration. Likewise, the lesions progressed to more posterior locations with increasing duration and concentration of formaldehyde exposure.
- Coherence: Precancerous dysplastic lesions were induced in rats and mice, sometimes at lower formaldehyde concentrations.
- Biological Plausibility: Mechanistic changes consistent with cancer development in nasal tissues were observed across species, including rats, mice, and monkeys. In F344 rats chronically exposed to formaldehyde, a clear temporal, dose-responsive, and biological relationship was observed in the appearance of genotoxicity, sustained epithelial damage, cellular proliferation, and eventual tumor development (see MOA synthesis below). This provides strong plausibility for the observed effects.

#### Evidence on Mode of Action

As described above, formaldehyde exposure has been associated with elevated incidence of carcinomas in human URT tissues, with the strongest evidence for nasopharyngeal and sinonasal tumor formation. Formaldehyde inhalation reproducibly induces squamous cell carcinomas (SCC) in the nasal passages of F344, Sprague Dawley, and Wistar rats (obligate nose-breathers), as well as polypoid adenomas (PA); SCCs and PAs are both rare tumors in rats, with background frequencies of ≤0.3% and ≤0.04%, respectively (Poteracki and Walsh, 1998; Chandra et al., 1992; Brown et al., 1991). SCCs were also elevated in the anterior nasal passages of chronically exposed B6C3F_1_ mice [background frequency of 0/2,818; (Brown et al., 1991)], but not in hamsters. Formaldehyde-associated SCCs and PAs originate in the nasoturbinates, maxilloturbinates, or lateral wall of the nasal cavity, and likely arise from the same target cell population (i.e., the nasal respiratory or transitional epithelium). The neoplastic response to formaldehyde exposure in rat nasal epithelium appears to be complex; SCC incidence is dramatically induced at exposure levels associated with other proliferative epithelial pathology, increasing from 1% at 7 mg/m^3^ to 60% at 18 mg/m^3^ in chronically exposed F344 rats. In contrast, relatively low frequencies of PAs are induced at concentrations ranging from 2.5 to18 mg/m^3^, with PA incidence increasing moderately to a maximum of 10% at 18 mg/m^3^ (see Table 3-37). SCCs and PAs are similarly induced in Sprague Dawley rats, and although nasal tumor incidence may be somewhat lower in Wistar rats, studies in the latter strain provide some evidence of tumor induction following subchronic exposure with lifetime follow-up.

Following inhalation exposure at analogous POE tissues in humans (nasal, buccal, and nasopharyngeal epithelium), nonhuman primates (nasal and extranasal respiratory and transitional epithelium, larynx, trachea, and carina), and rodents (nasal respiratory and transitional epithelium), evidence exists supporting the evaluation of a cancer mode of action (MOA). Among a variety of influential forces, two primary mechanistic considerations appear to contribute, both directly and indirectly, to tumorigenesis resulting from formaldehyde exposure at POE tissues: genotoxicity-associated mutagenicity, and cytotoxicity-induced regenerative proliferation. Furthermore, formaldehyde may stimulate nasal epithelial cell proliferation to some extent, even in the absence of frank tissue cytotoxicity. Instead of considering independent, sequential series of key events for each of these mechanistic considerations, evidence for genotoxicity and mutagenicity, cellular proliferation (independent from tissue pathology), and cytotoxicity-induced regenerative tissue proliferation is evaluated in an integrated manner, whereby hypothesized mutagenesis and increased cellular turnover initiate and then augment URT carcinogenesis as a function of exposure duration, periodicity, and tissue dose. This approach is consistent with the observation that, while mitogenesis can drive rodent tumor prevalence, it may not supplant the contribution of mutagenicity to chemically induced carcinogenesis (Ames and Gold, 1990).

Much of the available evidence relevant to these mechanistic considerations is discussed in detail in the prior sections on URT cancer data in human and animal studies, as well as in Sections 3.2.3 and 3.2.4, and in Appendix C.3 (genotoxicity) and C.7 (MOA information for noncancer respiratory effects). Herein, these findings are summarized and integrated into a proposed cancer MOA network to serve as a framework for the evidence evaluation and MOA analysis (see Figures 3-24 to 3-26). The evidence is synthesized with an emphasis placed on observations from humans and experimental animals repeatedly exposed to formaldehyde via the inhalation route, evaluated following the Bradford Hill considerations (U.S. EPA, 2005a), and conclusions are discussed in the context of URT carcinogenesis proceeding via this hypothesized, integrated cancer MOA. While evidence from biochemical investigations or cells cultured in vitro is not exhaustively described, pertinent observations are presented when useful in providing a mechanistic interpretation to effects described in vivo, when the available in vivo evidence is limited or nonexistent, or does not inform the effect under consideration. Only results from studies reporting some quantitative estimate of formaldehyde exposure concentration were synthesized, due to a general abundance of information relevant to the mechanistic considerations, and relative paucity of studies failing to provide formaldehyde exposure estimates. Evidence informing other modulating or modifying effects such as immune dysfunction and oxidative stress, DNA repair inhibition, and epigenetic alterations are also discussed briefly (for more detail see Appendices C.3 and C.7), while evidence for systemic genotoxicity and immune system effects outside the URT as relevant to carcinogenesis are primarily discussed elsewhere (see Section 3.3.3, Evidence on Mode of Action). While these factors may contribute significantly at various stages of URT carcinogenesis to the mechanistic considerations described above, the limited available data preclude evaluating their independent contribution to the formaldehyde URT cancer MOA. Likewise, while various aspects of this analysis may be directly relevant to formaldehyde exposure by other routes, or cancer at other (i.e., distal) tissue locations, this discussion is focused on cancers at POE tissues (i.e., the URT) following inhalation exposure.

##### Summary of genotoxicity and mutagenicity

This overall summary is relevant to MOA interpretations for both URT cancers (this section) and lymphohematopoietic cancers (see Section 3.3.3). Formaldehyde is a direct-acting chemical that has been shown to be genotoxic or mutagenic in a variety of in silico and in vitro test systems; experimental animals including mice, rats, and monkeys; as well as in humans. Formaldehyde exposure typically induces genotoxicity, mutagenicity, or related endpoints in a concentration- and duration-dependent manner, including deletions and point mutations; DNA-protein and DNA-DNA crosslinks (DPX and DDC, respectively) and DNA mono (hmDNA) adducts; clastogenic-related effects such as micronuclei (MN) and chromosomal aberration (CA) formation, as well as sister chromatid exchanges (SCEs), single-strand and double-strand breaks (SSBs, DSBs, respectively); and unscheduled DNA synthesis (UDS), DNA repair inhibition, and cellular transformation. For a comprehensive description of the evidence on formaldehyde genotoxicity, see Appendix C.3, which includes a summary table of genotoxicity endpoints investigated across the test systems most relevant to human inhalation exposure and, when possible, separates the results into respiratory- versus nonrespiratory-related tissues or systems.

This evaluation emphasizes the experiments interpreted to best inform the potential for genotoxicity in humans following inhalation exposure to formaldehyde, and therefore focuses on in vivo studies in mammalian species. In addition, the relative importance of the specific genotoxic endpoints was considered when prioritizing results in the synthesis of epidemiological evidence for genotoxicity. For example, it has been shown that increased frequency of CAs and MN are associated with increased cancer mortality, and these endpoints are considered by EPA to be highly relevant to the assessment of genotoxicity in humans (U.S. EPA, 2005a; Bonassi et al., 2004b; Bonassi et al., 2007; Bonassi et al., 2008). SSBs and DSBs in DNA indicate genetic instability and are also considered by EPA to be highly relevant to the assessment of genotoxicity for humans, while increased frequencies of sister chromatid exchange (SCE) are less strongly associated with cancer mortality (Bonassi et al., 2004a).

Inhaled formaldehyde primarily encounters cellular macromolecules at POE tissues, including both nasal and buccal epithelial cells in humans, while preferentially affecting the nasal epithelium in rodents, which are obligate nose-breathers. In these barrier tissues, formaldehyde can interact directly with DNA, resulting in DPX and DDC, DNA mono (hmDNA) adducts, SSBs, MN, and CAs. Furthermore, cells in the lower respiratory tract (LRT) and tissues distal to the initial point of exogenous formaldehyde exposure, such as peripheral blood lymphocytes (PBLs), are also potential targets of formaldehyde genotoxicity.

Neither DPX nor hmDNA adduct levels have been assessed specifically in nasal or buccal tissues from formaldehyde-exposed human workers, although occupational exposure to formaldehyde was associated with a significant exposure- and duration-related increase in DPX formation in PBLs. Formaldehyde-induced DPXs in the URT of rats and nonhuman primates in a dose-responsive manner across several studies. The predominant location of DPX formation varied due to anatomical differences in the nasal physiology and breathing patterns of primates versus rodents; however, the distribution of DPXs in rat nasal tissues corresponded to sites of tumor incidence, cell proliferation, and cytotoxicity. hmDNA monoadducts have been observed in the nasal epithelium of rats and the maxilloturbinate regions of rhesus monkeys following formaldehyde exposure, as well as in cell-free systems, and cultured cell lines including human nasal epithelial cells.

The majority of occupational studies have associated formaldehyde exposure with increased MN formation in human nasal or buccal epithelial cells, predominantly forming centromere-negative micronuclei suggesting clastogenic effects. Although no MN in nasal tissues were observed in one short-term, high-dose rodent inhalation study, MN were consistently induced in different mammalian cells in vitro. In addition, long-term occupational exposure was associated with significantly increased MN in PBLs, and aneugenicity appears to be the predominant effect in peripheral tissues (see Section 3.3.3). Exposure to formaldehyde also was associated with significantly increased CAs in PBLs of human workers, as well as in rodents from a short-term, high-dose study. Formaldehyde also induced CAs in rat pulmonary lavage cells, as well as hamster and primary human cells in vitro. Exposure-related increases in SSBs were observed in rat nasal tissues in one experimental study and in several studies of PBLs from exposed workers and rodents. Occupational exposure to formaldehyde caused increased mutant p53 protein expression in the serum of exposed workers, while cell lines derived from formaldehyde-induced rat nasal SCCs showed p53 mutations. Across the available database, formaldehyde consistently induces various endpoints consistent with mutagenicity, such as base pair mutations, deletions, insertions and point mutations, SCEs, SSBs, UDS, and DNA repair inhibition in various cells in vitro, in experimental animal models in vivo, as well as in exposed humans.

Formaldehyde is genotoxic. This conclusion is supported by several streams of evidence including observations of CAs, MN, and SSBs in exposed humans across a range of studies, occupations, and exposure scenarios, with supporting, similar findings in exposed rodents and in vitro systems, and consistent observations of DPXs detected in multiple experimental systems, showing a pattern of concentration-dependent increases. Together, these multiple streams of evidence (from human, animal, in vitro and nonmammalian systems) converge to clearly indicate that formaldehyde is genotoxic in most systems tested, is mutagenic in systems specifically evaluating genetic or chromosomal mutations, and exhibits strong evidence for mutagenicity in the URT of rodents and humans following inhalation exposure.

##### Summary and integration of mechanistic pathways into a cancer mode of action

The evidence pertaining to URT carcinogenesis following formaldehyde exposure was assembled into a putative URT cancer MOA network highlighting the potential contributions of genotoxicity and cytotoxicity-induced regenerative proliferation (see Figure 3-24), as well as incorporating the influences of increased cell turnover independent of tissue pathology, underlying chronic inflammation and epigenetic activity as prime examples of other considerations that can interact with and further modify the primary mechanisms propelling formaldehyde-induced URT cancer, in addition to potentially contributing independently. Table 3-38 presents a concordance summary view of the available evidence (Meek et al., 2014), illustrating the exposure concentration and duration required to either elicit or amplify formaldehyde-associated effects in the URT of F344 rats (the model species most sensitive to SCC development with the most diverse and robust data set available). These rat data are informative of the mechanistic pathways of primary concern, including genotoxicity endpoints as an indicator of mutagenic potential; reports of tissue pathology including hyperplasia, squamous metaplasia, dysplasia, and necrosis; cellular DNA synthesis as an indicator of epithelial proliferation rate (independent of cause); as well as formaldehyde-associated tumor induction (see Section 3.2.5, Respiratory Tract Cancers in Animal Studies). These interrelated streams of evidence are summarized separately (below) and then integrated into a composite MOA, which is evaluated in subsequent sections.

Figure 3-24 An integrated cancer mode-of-action (MOA) network for the URT

Various effects occur in a manner dependent upon duration and magnitude of formaldehyde (FA) inhalation exposure. Primary mechanistic considerations in call-out boxes are described in the following tables and figures (blue/genetic damage, see Table 3-39; green/formaldehyde-induced proliferation without damage, see Table 3-40; red/tissue and cellular damage, see Tables 3-40 and 3-41) with evidence identified from the formaldehyde database as possibly informative of molecular mechanisms. These mechanistic considerations or modifying factors are consistent with those factors described as cancer hallmarks, enabling, or key characteristics of carcinogens (Smith et al., 2016; Hanahan and Weinberg, 2011).

Table 3-38 Concordance of temporal and dose-response relationships among formaldehyde effects induced in F344 rat nasal epithelium in vivo

F344 Rats | | Time (months); → | | | Time (months); →
F344 Rats | | 0-3 | 4-12 | 13-28 | 0-3 | 4-12 | 13-28
F344 Rats | | Genotoxicity ^a^ | | | Necrosis ^b^
Exposure (mg/m^3^) | 0-2; ↓ | + | ND | ND | - | - | -
Exposure (mg/m^3^) | 2-7; ↓ | ++ | ND | ND | -/+ | - | -
Exposure (mg/m^3^) | >7; ↓ | +++ | ND | ND | ++ | + | +
| | Hyperplasia and/or metaplasia ^c^ | | | DNA synthesis ^d^ ^,^ ^e^
Exposure (mg/m^3^) | 0-2; ↓ | - | - | + | -/+ | _^f^ | _^f^
Exposure (mg/m^3^) | 2-7; ↓ | -/+ | + | ++ | + | _^f^ | _^f^
Exposure (mg/m^3^) | >7; ↓ | + | ++ | +++ | +++ | ++^f^ | ++^f^
| | Tumorigenesis (polypoid adenoma) ^g^ | | | Tumorigenesis (squamous cell carcinoma) ^g^
Exposure (mg/m^3^) | 0-2; ↓ | - | - | - | - | - | -
Exposure (mg/m^3^) | 2-7; ↓ | - | - | + | - | - | -/+
Exposure (mg/m^3^) | >7; ↓ | - | - | ++ | - | + | +++

Male F344 rats were the most widely evaluated sex/strain/species/evaluated, but observations were comparable between rat sexes, where available. The presence or absence of treatment-related effects across all available studies (as determined by EPA review) in or near the nasal anterior lateral meatus (ALM, where specified, generally within Level II), were depicted as follows: “−” indicates the absence of effects; “ND” indicates no data available for the specified endpoint/dose/time combination; −/+ indicates an equivocal response, or evidence limited to the highest extreme of the exposure range indicated; +, ++, +++ indicate the presence of an exposure-related effect, with symbol number corresponding to increasing magnitude, incidence, or severity, relative to concurrent controls and other exposure level/duration entries within an effect category (see Section 3.2.4 and Appendix C.3).

a Includes DNA-protein and DNA-DNA crosslinks or increases in N^2^-hmdG DNA adducts attributed to exogenous formaldehyde exposure.

b Direct evaluation necrosis was not frequently reported, and apoptosis has not been directly measured; significant exposurerelated tissue destruction was inferred from pathological determination of necrosis, erosion, disarrangement, or atrophy of the nasal epithelium.

c Tissue reactive or adaptive responses to irritant or cytotoxic effects were determined by evaluating hyperplasia or squamous metaplasia (typically combined in reporting by study authors) of the nasal respiratory or transitional epithelium; however, the biochemical stimulus of this tissue reaction remains unclear, as such areas of hyperplasia could also include areas of dedicated preneoplastic foci.

d DNA label incorporation as a measure of proliferation at the individual cell level in the ALM was measured by incorporation of BrdU, [^3^H]-thymidine or [^14^C]-formaldehyde into DNA, and reported as an index normalizing affected (positive) cells as a fraction of the total respiratory epithelium (see detailed summary in Appendix C.7.1).

e DNA synthesis has been evaluated following both continuous and intermittent exposures; while effects of continuous exposure are depicted herein for purposes of drawing comparisons across similar exposure scenarios, intermittent exposure may be also informative for some human exposure scenarios.

f Results from a single study reporting rat nasal epithelial cell DNA label incorporation following 26, 52, or 78 weeks of exposure (Monticello et al., 1996).

g Both polypoid adenomas (PA) and squamous cell carcinomas (SCC) were described as likely arising from the respiratory or transitional epithelium, typically on or near the ALM. However, SCCs were typically associated with areas of hyperplasia or squamous metaplasia, whereas PAs were not.

Formaldehyde directly adducts DNA and proteins, causing dose-responsive increases in DNA-protein (DPX) or DNA-DNA (DDC) crosslinks, as well as DNA mono deoxyguanosine (hmdG) adducts (see Table 3-38, also see Appendix C.3). Evidence from humans and rodents suggests that formaldehyde exposure can lead to increasing levels of reactive oxidative species (ROS) and possibly inhibit cellular detoxification mechanisms (see Appendix C.7), which would be expected to further exacerbate oxidative damage to cellular constituents and DPX formation. Following these initial effects, single-strand DNA breaks could be created more frequently, and DNA repair could be inhibited, possibly leading to an accumulation of genetic damage at the chromosome (clastogenicity) and sequence level (gene mutations). While the specific nature of persistent genetic damage leading to URT cancer following formaldehyde exposure is unclear, heritable changes in genetic material are a prerequisite step for carcinogenesis following a mutagenic mode of action. The observations most relevant to genotoxic effects and sequelae to URT neoplasia are summarized in Table 3-39.

Table 3-39 Genotoxicity and mutagenicity in the upper respiratory tract

Observations from the available in vivo database (see Appendix C.3 for details)^a,b^ | Exposure level (mg/m^3^)^c^ | Statistical associations^d^
Human
Acute or short-term exposure: controlled
- No effect or limited ↑ on MN incidence in nasal/buccal epithelial tissue | ≤1, or 17 mg/m^3^-hrs ^e^ | NR
Subchronic exposure: repeat environmental (pathology and medical students)
- ↑ MN incidence in nasal and buccal epithelium, stronger association in centromere-negative MN | 0.5−2; [0.07−5] | NR and −/+ assoc. w/↑ CE
Chronic exposure: repeat occupational/environmental
- ↑ Binucleation, but not nuclear bud or MN frequency, in buccal epithelium from furniture workers | 0.04−0.1; [NR] | + assoc. w/↑ [C] No assoc. w/↑ D
- ↑ MN frequency in nasal epithelium from workers | 0.1−1; [0.05−5] | NR
- ↑ MN frequency in buccal epithelium from anatomy/pathology faculty and staff, laboratory or factory workers | 0.2−NR; [0.05−5] | + assoc. exposed:referent + association w/↑ D
Nonhuman primate
Acute or short-term exposure: controlled
- ↑ DPX in the nasal mucosa; larynx, trachea, and/or carina; maxillary sinuses and lower respiratory tract of rhesus monkeys | ≥0.9; ≥2; 7 | − assoc. w/↑ distance from POE
- ↑ Exogenous FA ^13^CD_2_-N^2^-hmdG adducts and DPXs in maxilloturbinates of cynomolgus monkeys | ≥2 | + assoc. w/↑ [C]
Rodent
Acute or short-term exposure: controlled
- ↑ DPX in the nasal epithelium; no effect in bronchoalveolar lavage fluid or nasal olfactory mucosa of F344 rats | ≥0.4; ≥18 | − assoc. w/↑ distance from POE
- ↑ Exogenous FA ^13^CD_2_-N^2^-hmdG adducts and DPXs in nasal epithelium of F344 rats | ≥0.9 | + assoc. w/↑ [C], D
Subchronic exposure: controlled
- ↑ DPX in the nasal epithelium of F344 rats | ≥0.9 | − assoc. w/↑ distance from POE
- No effect on MN incidence in nasal epithelium of F344 rats | ≤18 | NR

a Treatment-associated increase (↑), micronucleus (MN), DNA-protein crosslinks (DPX), DNA monomethyl deoxyguanosine adducts resulting from exogenously administered formaldehyde (FA ^13^CD_2_-N^2^-hmdG), single-strand DNA breaks (SSBs).

b The earliest duration reported by the study authors to elicit the specified effect is noted for controlled exposure studies, or the mean duration reported in epidemiological studies; multiple values are provided in cases where the study authors described only a range of exposure durations, or to represent a range of average durations from a collection of similar epidemiological or experimental reports.

c For experimental studies, lowest effective concentrations (LEC) are presented, while for individual epidemiological studies, mean exposures are listed, otherwise the range of mean exposures is presented to represent a collection of studies reporting similar effects, with the overall range reported in individual studies or collections in [ ]; determinations were made by EPA review considering potentially biologically relevant effects that were attributed by the study authors to formaldehyde exposure; “≥” indicates that higher exposures were evaluated that also indicated an exposure-related effect. Where no effect was reported, the highest ineffective concentrations (HIC), or ranges of exposure are indicated; “≤” indicates that concentrations lower than the HIC were also evaluated.

d Results of association, regression, correlation, or trend analysis as reported by study authors; “NR” indicates that either associations were not evaluated or that no significant associations (assoc.) were reported; positive (+), weakly positive (−/+) associations, inverse association (−); with (w/), exposure duration (D), cumulative exposure (CE), exposure concentration ([C]), apical portal of entry (POE).

e This study employed a complex and variable exposure protocol, with individuals experiencing 17 mg/m^3^-hours of cumulative formaldehyde exposure distributed throughout a period of 40 hours over 10 workdays (2 weeks).

f Results presented from respiratory or transitional epithelial tissue generally described as located in “Level II” of the anterior rodent nasal passages, including the nasal lateral meatus, septum, naso- and maxilloturbinates, as described in Section 3.2.4.

In addition to directly damaging DNA, formaldehyde inhalation can cause a number of pathological cellular changes in the URT, such as inhibited mucous flow and decreased ciliary beat, rhinitis and inflammation, ciliastasis, cilia loss, and possibly sporadic epithelial proliferation at low-to-moderate exposure levels that elicit marginal increases in frank tissue toxicity as evidenced by a lack of necrosis, epithelial degeneration, or squamous metaplasia in the nasal passageways (see Section 3.2.4). Any molecular mechanisms responsible for such respiratory epithelial proliferation remain to be determined, but could include some of the cytokines and eicosanoids associated with URT inflammation and leukocyte extravasation, epigenetic activation, or suppression of cell cycle regulatory machinery through changes in gene regulation, including miRNA, loss of contact-inhibition signaling, or even direct stimulation of epithelial mitosis via adduction of growth factor-signaling mediators (see Appendix C.7 for the evidence available on some of these potential events). Accelerated cell cycle progression can increase the rate of random genotoxic events in proliferating cells (indirect genotoxicity), which—if improperly repaired due to insufficient delay in G1 phase, failure to arrest in S phase, or deficiency of DNA repair machinery—could lead to heritable mutations and eventually URT neoplasia (Branzei and Foiani, 2008). Tissue stem cell proliferation rate and the contribution of this random or “background” mutagenesis to human lifetime cancer risk has been proposed to be significant for a variety of tissues (Tomasetti and Vogelstein, 2015), although the relevance, magnitude, and scope are still under debate (Wodarz and Zauber, 2015; Wild et al., 2015; Rozhok et al., 2015). Experimentally, the magnitude of formaldehyde-induced DNA synthesis is dramatically increased as a function of concentration and, to a lesser extent, duration, reaches maximal levels after 1−3 months with short-term or subchronic exposure, and then appears to diminish in the only study that looked at changes after exposure longer than 13 weeks (see Appendix C.7). Observations from direct DNA labeling studies are summarized in Table 3-40 (scenarios involving cytotoxic exposures are described below).

Table 3-40 Direct measurements of DNA synthesis in the upper respiratory tract

Observations from the available in vivo database (see Appendix C.7.1 for details on proliferation)^a,b^ | Exposure level (mg/m^3^)^c^ | Statistical associations^d^
Nonhuman primate
Acute―subchronic exposure: controlled
- ↑ Epithelial cell proliferation in nasal and extranasal transitional and respiratory epithelium of rhesus monkeys | 7 | − assoc. w/↑ D, distance from POE
Rodent ^e^
Acute exposure: controlled
- ↑ Epithelial cell proliferation in nasal septum, lateral meatus, or turbinates of Wistar rats; in the anterior nose (not otherwise specified) in Sprague Dawley rats | ≥4; ≥3 | NR; NR
- ↑ Epithelial cell proliferation in the nasal lateral meatus, or maxilloturbinates in F344 rats | ≥7 | − assoc. w/↑ D; + assoc. w/↑ CE^f^
- ↑ Epithelial cell proliferation in the nasal lateral meatus, or nasoturbinates in B6C3F_1_ mice | ≥15 | − assoc. w/↑ D; + assoc. w/↑ CE^f^
Subchronic exposure: controlled
- ↑ Epithelial cell proliferation in nasal septum, turbinates, or lateral meatus of Wistar rats | ≥4 | + assoc. w/↑ [C] and not CE
- ↑ Epithelial cell proliferation in the nasal lateral meatus, septum, and/or turbinates of F344 rats | ≥3−7^g^ | − assoc. w/↑ distance from POE; + assoc. w/↑ [C], D
Chronic exposure: controlled
- ↑ Epithelial cell proliferation in the nasal lateral meatus in F344 rats | ≥12 | − assoc. w/↑ D, distance from POE

a Treatment-associated increase (↑).

b The durations reported by the study authors to elicit the specified effect are noted for controlled exposure studies; multiple values represent different durations from several experimental reports.

c Lowest effective concentrations (LEC) are presented for experimental studies, as determined by EPA review considering potentially biologically relevant effects that were attributed by the study authors to formaldehyde exposure; “≥” indicates that higher exposures were evaluated which also indicated an exposure-related effect.

d Results of association, regression, correlation, or trend analysis as reported by study authors; “NR” indicates that either associations were not evaluated or that no significant associations (assoc.) were reported; positive (+) or inverse association (−); with (w/), exposure duration (D), cumulative exposure (CE), exposure concentration ([C]), apical portal of entry (POE).

e Results presented from respiratory or transitional epithelial tissue generally described as located in “Level II” of the anterior rodent nasal passages, including the nasal lateral meatus, septum, naso- and maxilloturbinates, whereas “Level I” commonly included the high-flux region and nose tip, as described in Section 3.2.4.

f These associations are for “Level I” epithelial cells; only exposure concentration ([C]) was positively associated with cells in “Level II.”

g LEC reported varied among reports from different authors and following exposures of different durations.

At higher, cytotoxic exposure levels, regenerative tissue proliferation concomitant with and resulting from cytotoxic epithelial pathology (including squamous hyperplasia, metaplasia, and dysplasia, with or without evidence of frank necrosis; discussed in Section 3.2.4) occurs in an exposure concentration- and duration-dependent manner. The relative contribution of exposure concentration and duration to this process may not be equal, particularly for events that segue from hyperplasia (exposure duration appears to be substantially more important to the development of metaplasia in laboratory animals than to the development of hyperplasia; see Section 3.2.4); however, specific data defining the relative contributions are unavailable. Metaplasia or hyperplasia is induced at moderate to high exposure levels after even short-term exposure, and extending the duration generally both increases the severity of nasal tissue pathology observed and decreases the exposure concentration necessary to elicit significant cytotoxicity (see Section 3.2.4). Pathological indications of significant epithelial necrosis in F344 rats are primarily reported following exposure to relatively high concentrations, with similar results in Wistar or Sprague Dawley rats, although occasionally necrosis is reported at more moderate exposure levels. Under these conditions, the tissue rhinitis/inflammation, macromolecule adduction, or inhibition of cellular function is presumably severe enough, possibly in conjunction with tissue glutathione (GSH) depletion, to trigger cell death and significant regenerative pathology in the nasal respiratory or transitional epithelium. Together, these effects can increase damage from all sources to cellular constituents (e.g., membrane lipids and proteins, cytosolic proteins, DNA), and amplify genotoxicity while simultaneously decreasing the capacity for and fidelity of DNA repair. Thus, both direct and indirect effects of formaldehyde exposure at these levels can feed forward to increase insurmountable cellular toxicity. Cytotoxicity and death of more sensitive cells in the respiratory epithelial tissue compartment could select for and trigger compensatory proliferation among more resistant cells in the population, possibly including the division and differentiation of local pluripotent stem cells, all of which may replicate to replenish the damaged nasal mucosa. The magnitude of these tissue proliferative effects may also fluctuate as the result of epithelial tissue responses to chronic, continuous (i.e., metaplastic differentiation to a squamous phenotype) versus episodic (variable pathology) exposure scenarios. In this manner, formaldehyde exposure may accelerate proliferation as a field effect at the epithelial tissue level, causing genotoxicity and mutagenesis in both actively proliferating (direct and indirect genotoxicity) and more quiescent cells (direct genotoxicity only). Observations relevant to cytotoxic tissue pathology and regenerative proliferation are summarized in Table 3-41.

Table 3-41 Epithelial pathology, cytotoxicity, and regenerative proliferation in the upper respiratory tract

Observations from the available in vivo database (see Appendix C.7 for details)^a,b^ | Exposure level (mg/m^3^)^c^ | Statistical associations^d^
Human
Acute Exposure: Controlled ^e^
- ↑ Nasal mucosal membrane swelling; nasal and throat irritation | ≥0.07; ≥0.3 | NR;; + assoc. w/↑ [C]
- ↓ Nasal mucociliary function, mucus flow rate; ↑ rhinitis and permeability index | ≥0.3; ≥0.5 | No assoc. w/D; NR
Chronic Exposure: Repeat Occupational/Residential
- ↓ Nasal patency (airway volume) | 0.01; [0.003−0.02] | − assoc. w/dust, NO_2_, mold
- ↑ General symptoms of rhinitis, URT irritation, or inflammation | 0.05−1; [0.01−2] | + assoc. w/↑ [C],; No assoc. w/D
- ↓ Nasal mucociliary function | 0.3; [0.05−0.5] | No assoc. w/D
- ↑ Nasal hyperplasia, keratinization, or squamous metaplasia | 0.3−NR; [0.02−2.5] | No assoc. w/D; + assoc. w/age >50
Nonhuman Primate
Acute Exposure: Controlled
- ↓ Cilia content and ↑ hyperplasia or squamous metaplasia in nasal epithelium, nasopharynx, and larynx of rhesus monkeys | 7 | − assoc. w/↑ distance from POE
Subchronic Exposure: Controlled
- ↑ Squamous metaplasia and hyperplasia in nasal epithelium, nasopharynx, and larynx of rhesus monkeys | 7 | + severity w/↑ D; − assoc. w/↑ distance from POE
- ↑ Squamous metaplasia and hyperplasia in nasal turbinates of cynomolgus monkeys | ≥4 | + assoc. w/↑ [C]
Rodent ^f^
Acute Exposure: Controlled ^g^
- ↑ Nasal rhinitis, hyperplasia, or squamous metaplasia in Wistar rats | 4 | NR
- ↓ Microvilli content in nasal epithelial cells, ↓ nasal mucociliary function, flow rate; ↑ nasal squamous metaplasia of F344 rats | ≥3; ≥7 | − assoc. w/↑ [C], D;; NR
- ↑ Nasal squamous metaplasia or hyperplasia in Swiss-Webster or B6C3F_1_ mice | ≥4 | NR
Subchronic Exposure: Controlled
- ↑ Nasal rhinitis, hyperplasia, or squamous metaplasia; ↓ cilia content of nasal septa epithelium in Wistar rats | ≥4; 4 | + assoc. w/↑ [C] and not CE; NR
- ↑ Nasal hyperplasia or squamous metaplasia in F344 rats | ≥7−12 | − assoc. w/↑ distance from POE
- ↑ Nasal squamous metaplasia and seropurulent inflammation in B6C3F_1_ mice | ≥12 | NR
Chronic Exposure: Controlled
- ↑ Nasal rhinitis, hyperplasia, or squamous metaplasia in Wistar and F344 rats | ≥1 and ≥3 | NR and + assoc. w/↑ [C], D
- ↑ Nasal squamous metaplasia (but not rhinitis or hyperplasia) in Sprague Dawley rats | 18 | NR
- ↑ Nasal rhinitis, hyperplasia; nasal squamous metaplasia and dysplasia in B6C3F1 mice | ≥3; ≥12 | NR; NR

a Treatment-associated increase (↑), treatment-associated decrease (↓), hours (hrs), upper respiratory tract (URT).

b The earliest duration reported by the study authors to elicit the specified effect is noted for controlled exposure studies, or the mean duration reported in epidemiological studies; multiple values are provided in cases where the study authors described only a range of exposure durations, or to represent a range of average durations from a collection of similar epidemiological or experimental reports.

c For experimental studies, lowest effective concentrations (LEC) are presented, while for individual epidemiological studies, mean exposures are listed, otherwise the range of LECs or mean exposures are presented to represent a collection of studies reporting similar effects, with the overall range reported in individual epidemiological studies or collections shown in brackets ([ ]); determinations were made by EPA review considering potentially biologically relevant effects that were attributed by the study authors to formaldehyde exposure; “≥” indicates that higher exposures were evaluated that also indicated an exposurerelated effect.

d Results of association, regression, correlation, or trend analysis as reported by study authors; “NR” indicates that either associations were not evaluated or that no significant associations (assoc.) were reported; positive (+), inverse association (−); with (w/), exposure duration (D), cumulative exposure (CE), exposure concentration ([C]); apical portal of entry (POE).

e Due to the abundance of acute exposure human studies, only those rated as high or medium confidence are summarized, as described in Appendix C.7.

f Results presented from respiratory or transitional epithelial tissue generally described as located in “Level II” of the anterior rodent nasal passages, including the nasal lateral meatus, septum, naso- and maxilloturbinates, as described in Section 3.2.4.

g Due to the abundance of acute exposure rodent studies, only those rated as high or medium confidence are summarized, as described in Appendix C.7.

Relationships among the various events discussed above are integrated into a mechanistic network depicted in Figure 3-25, along with the modifying factors of chronic airway inflammation, oxidative stress, and epigenetic effects, which are also likely to stimulate or enhance URT tumorigenesis. Together, these primary mechanistic events and modifying factors form potential adverse outcome pathways (AOP), which are illustrated as a network of interconnected events [adverse outcome network (AON)], with some duplication of events across individual pathways for clarity (see Figure 3-26). These figures highlight various interactions among mechanistic elements for which some evidence exists in the formaldehyde database. They also facilitate the discussion and evaluation of this evidentiary support. The figures are not intended to illustrate every possible relationship among various aspects of formaldehyde toxicity and do not represent an attempt to exhaustively list all possible carcinogenic mechanisms. Furthermore, the understanding of how such signaling circuits actually operate in human carcinogenesis is still fragmentary and the current subject of intense study (Weinberg, 2014). The following section serves to evaluate the supporting evidentiary data pertaining to the events depicted in these figures.

Figure 3-25 Mechanistic relationships relevant to URT carcinogenesis

Integration of the molecular evidence available for the spectrum of formaldehyde- [FA-] related health effects pertinent to upper respiratory tract carcinogenesis summarized in the previous sections. Endpoints are depicted with varying degrees of support (with solid lines representing evidence from exposure in vivo, or consistent findings across multiple types of in vitro evidence). The identification of “reliable evidence” and related conclusions depicted in this figure are based primarily on evaluations conducted elsewhere (i.e., robust or moderate evidence described in Appendix C.7). Plausible relationships are illustrated in a manner consistent with the cancer MOA schematic in Figure 3-24, including the hallmarks and enabling characteristics of cancer outlined therein.

Figure 3-26 Network of adverse outcome pathways relevant to URT carcinogenesis

Integration of the possible key events in pathways describing the role of genotoxicity and mutagenicity, cellular mitogenesis, and cytotoxicity and regenerative tissue proliferation in URT carcinogenesis following formaldehyde exposure. Endpoints are depicted with varying degrees of support (with solid lines representing evidence from exposure in vivo, or consistent findings across multiple types of in vitro evidence), with plausible relationships as hashed arrows, and possible feed-back loops illustrated as dotted reverse-facing blue lines. Boxes of varying colors represent events associated with related groups of key characteristics of carcinogens (Smith et al., 2016); electrophilicity, genotoxicity, and DNA repair elements are in blue, cell death and proliferation elements are in green, while the influence of chronic inflammation, oxidative stress, and epigenetic alterations are depicted as factors modifying the network in orange, purple, and yellow, respectively.

##### Evaluation of experimental support for the hypothesized mode of action

###### Genotoxicity

DNA-protein crosslinks (DPXs) were significantly elevated in the respiratory tracts of rhesus monkeys after 3 days of inhalation exposure, with lowest effective concentrations (LEC) increasing with anatomical distance from the apical POE, from 0.9 mg/m^3^ in the nasal turbinates, to 2 mg/m^3^ in the larynx, trachea, and carina (pooled samples), and 7 mg/m^3^ in maxillary sinuses and lungs (Casanova et al., 1991), demonstrating direct genotoxicity as an early effect in tissues analogous with sites of tumor formation in humans. In rats, increased DPX levels from exogenous formaldehyde were observed in the nasal lateral, medial, and posterior meatus (Casanova et al., 1994) or the entire nasal cavity of rats after ≥0.86 mg/m^3^ ^14^C-formaldehyde inhalation (Casanova et al., 1989), following single and multiple inhalation exposures over 0.25−81 days. Exogenous DPXs resulting from exposure to ^13^C, d_2_-labeled formaldehyde was reported in nasal passages from both nonhuman primates and rats. In rat nasal passages, DPX levels accumulated several-fold following 28 days of exposure to 2.5 mg/m^3^ and remained largely unchanged following 7 days of recovery postexposure (different time points were not evaluated in nonhuman primate studies, (Lai et al., 2016)). Interestingly, while DPX levels increased by 2-fold to 30-fold over control levels from 0.9 to 18 mg/m^3^ in rat nasal passages (NTP, 2010; Liteplo and Meek, 2003), the rate of DPX formation per unit of formaldehyde exposure (DPX/ppm exogenous formaldehyde) increased to a plateau at 7 mg/m^3^, where it remained constant from 7 to 18 mg/m^3^ (Swenberg et al., 2013; Casanova-Schmitz et al., 1984b). In both rhesus monkeys and F344 rats, DPX incidence was inversely associated with increasing anatomical distance from apical POE (Lam et al., 1985; Casanova-Schmitz and Heck, 1983; Casanova-Schmitz et al., 1984b; Casanova et al., 1989; Casanova et al., 1991; Casanova et al., 1994; Casanova and Heck, 1997). While increased DPX formation in human peripheral white blood cells (WBCs) has been positively associated with duration of exposure to concentrations ≥0.3 mg/m^3^ [(Shaham et al., 1996; Shaham et al., 1997; Shaham et al., 2003; Lin et al., 2013); see Appendix A.4], DPX levels have not been evaluated in analogous human POE tissues (i.e., nasal, buccal, or nasopharyngeal epithelium).

Bulky DNA adducts, such as DPX, can block progression of the DNA polymerase complex, possibly contributing to genotoxicity or cell death in the URT (for further discussions see Appendices A.4 and A.5.6; (Wong et al., 2012; Heck and Casanova, 1999)). After a single exposure in rats, the inhibition of DNA replication due to DPX blockage was also predicted to be significant at >7 mg/m^3^ (Heck and Casanova, 1999). While DNA replication was thought to be only marginally affected after a single exposure to lower concentrations (<1% at 1 mg/m^3^ in rats), this effect may increase in magnitude or impact with the accumulation of DPXs and DNA adducts resulting from repeated exposure, as discussed below. Although the mechanisms regulating these effects remain undetermined, exposures ≥7 mg/m^3^ are associated with increasingly severe epithelial pathology, cell death, and hyperproliferation in rat nasal passages following subchronic exposure, as well as dramatic increases in SCC formation after chronic exposure (see discussions of the specific animal evidence in Section 3.2.4 and earlier in this section, 3.2.5).

In addition to forming crosslinks, biochemical investigations have demonstrated that formaldehyde can react with DNA to form predominantly N^6^-hydroxymethyl-deoxyadenosine (N^6^-hmdA) and N^2^-hydroxymethyl-deoxyguanosine (N^2^-hmdG) adducts, with dA adducts more abundant than dG (Zhong and Hee, 2004; Cheng et al., 2008; Beland et al., 1984). While both DNA adducts have been detected in various tissues in vivo, likely resulting from endogenous formaldehyde reactivity, studies administering deuterium-labeled formaldehyde (^13^C, d_2_) have detected labeled N^2^-hmdG, but not N^6^-hmdA, in the URT epithelium of both rodents and nonhuman primates (see Table 3-42; (Lu et al., 2010b; Lu et al., 2011; Lu et al., 2012); see Appendix A.4; (Yu et al., 2015b; Swenberg et al., 2013; Moeller et al., 2011), as well as human HeLa cells in culture (Lu et al., 2012). The inability to detect ^13^C, d_2_-N^6^-hmdA was surprising, since ^13^C, d_2_-N^2^-hmdG is reliably quantifiable following low levels of exposure, and increases in an exposure-dependent manner in both rodents and nonhuman primates (Yu et al., 2015b; Swenberg et al., 2013); the reason for the apparent absence of ^13^C, d_2_-N^6^-hmdA adducts formed by reaction with exogenous formaldehyde remains unknown (see Appendix C.1). N^2^-hmdG adducts resulting from exogenous exposure were positively associated with exposure concentration in the nasal maxilloturbinates of cynomolgus monkeys after 2 days, with an LEC of 2 mg/m^3^ (Moeller et al., 2011), and also in the nasal epithelium of F344 rats after 1 to 28 days, with an LEC of 0.86 mg/m^3^ (Yu et al., 2015b; Lu et al., 2010b; Lu et al., 2011). However, formaldehyde exposure up to 0.37 mg/m^3^ in F344 rats failed to induce DPXs or hmDNA adducts in the nasal epithelium or in systemic tissues (Leng et al., 2019). As with DPXs, rat nasal N^2^-hmdG adduct formation was also positively associated with exposure duration, with adducts accumulating to levels ≥5 times higher after 28 days of exposure to 2.5 mg/m^3^ compared with single exposures; different time points were not evaluated in nonhuman primate studies (Yu et al., 2015b; Swenberg et al., 2013; Lu et al., 2010b). No studies have assessed the formation of exogenous hmDNA adducts in any tissues from humans exposed to formaldehyde.

Together with the above, acute exposure in rats and nonhuman primates appears to be sufficient to significantly increase formation of DPXs at an LEC of approximately 0.86 mg/m^3^ and exogenous N^2^-hmdG adducts at LECs of 0.86 and 2 mg/m^3^ in analogous nasal tissues from both species. The observation that both DPXs and N^2^-hmdG adducts are positively associated with exposure concentration in both nonhuman primates and rats (Yu et al., 2015b; Swenberg et al., 2013; Moeller et al., 2011; Lu et al., 2010b; Lu et al., 2011; Lai et al., 2016), and that they accumulate in rat nasal passages with repeat exposure (Yu et al., 2015b; Lai et al., 2016), is consistent with the hypothesis that DPXs may undergo spontaneous hydrolysis to form N^2^-hmdG adducts (Yu et al., 2015b). While some DPXs may undergo hydrolysis to form N^2^-hmdG adducts following exogenous formaldehyde exposure, other DPXs appear to be quite stable in vivo; it may be these latter DPXs that play a more important role in formaldehyde-mediated respiratory tract mutagenicity and carcinogenicity (NRC, 2011; Lai et al., 2016).

In addition to DNA adducts, strand breaks and cytogenetic endpoints have also been observed following formaldehyde exposure, and such damage can lead to heritable mutations, deletions, amplification, or chromosomal abnormalities if not successfully repaired. While DNA strand breaks have not been evaluated in apical POE tissues from rats or nonhuman primates, DNA SSB incidence was significantly increased in a concentration-dependent manner in both lung epithelial cells and PBLs from Sprague Dawley rats after 14 days of exposure to ≥6 mg/m^3^, in the absence of significant protein or lipid oxidation in lung tissue (Sul et al., 2007; Im et al., 2006), corresponding with increased lung cell apoptosis observed following 28 days of exposure to ≥7 mg/m^3^ (Aydin et al., 2014). Likewise, while strand breaks have not been measured in adult human URT tissues, increased SSBs have been reported in PBLs following occupational exposure to ≥0.3 mg/m^3^ (Lin et al., 2013; Costa et al., 2008; Aydın et al., 2013), (see Appendix C.3).

Unlike DNA stand-breaks, clastogenicity (in particular, MN formation) has been evaluated in human URT tissues. Acute, controlled exposures in healthy human volunteers yielded equivocal results; furthermore, MN incidences fell dramatically in both tissues during 21 days of postexposure monitoring (Zeller et al., 2011; Speit et al., 2007). Binucleation only, a proposed early event in MN formation, was elevated in buccal tissues from workers repeatedly exposed to low formaldehyde levels (mean location-specific concentrations of 0.04−0.11 mg/m3; (Peteffi et al., 2015). Although MN incidence was not significantly elevated in rat URT tissues after 28 days of exposure to ≤18 mg/m^3^ (see Table 3-42) (Speit et al., 2011; Neuss et al., 2010), the majority of human studies have reported significant MN induction in the buccal epithelium after 5−35 years of occupational exposures to higher concentrations, averaging ≥0.2 mg/m^3^ (see Table 3-42) (Viegas et al., 2010; Ladeira et al., 2011; Ladeira et al., 2013; Costa et al., 2019; Burgaz et al., 2001; Burgaz et al., 2002; Aglan and Mansour, 2018), and in the nasal epithelium of adults after an average of 7−11 years at ≥0.1 mg/m^3^ (Ye et al., 2005; Costa et al., 2008; Ballarin et al., 1992). Results in students from shorter- duration classroom exposures (60−90 days) to 0.5−2 mg/m^3^ have been lower in magnitude and less consistently positive, showing a stronger association between cumulative exposure and buccal versus nasal MN incidence and a stronger association with centromere-negative MN incidence, consistent with MN formation following DNA strand breakage (Ying et al., 1997; Titenko-Holland et al., 1996; Suruda et al., 1993). This hypothesized mechanism is consistent with the gene expression profile of human B-lymphoblastoid cells (Tk6) directly exposed to cytotoxic concentrations of formaldehyde in vitro, with transcript changes more akin to DNA-alkylating clastogenic agents than aneugenic spindle poisons (Kuehner et al., 2013). In buccal epithelium from human students or factory workers, MN incidence was positively correlated with exposure duration (p < 0.01) following exposure to 0.06−0.6 mg/m^3^ for ≥1 year (Viegas et al., 2010), and positively correlated with cumulative exposure in male (p = 0.01) or male + female (p = 0.06) student populations exposed to 0.5−2 mg/m^3^ for 90 days (Titenko-Holland et al., 1996; Suruda et al., 1993). Compared with the evaluations of URT tissues, cytogenetic endpoints have been more frequently evaluated in PBLs from occupational exposure cohorts (for further discussion, see Section 3.3.3 Evidence on Mode of Action, and Appendix C.3). Most of the studies conducted over the past 20 years have reported increased PBL MN incidence in formaldehyde-exposed humans, including the majority of studies reporting formaldehyde-associated increases in buccal or nasal MN incidence (Kirsch-Volders et al., 2014). Together with the above, the existing evidence consistently supports the association of MN induction in nasal and buccal tissue from human cohorts occupationally exposed to formaldehyde, in a manner temporally, biologically, and dose-responsively concordant with observations of nasopharyngeal and sinonasal carcinogenesis across a range of exposure scenarios and concentrations.

Similar MN induction in epithelial cells of the URT has also been associated with increased human cancer risk in other populations (Ramirez and Saldanha, 2002; Lippman et al., 1990). Independent of formaldehyde exposure, a strong correlation between POE (buccal) and systemic (PBL) MN incidence has also been reported in samples collected from >6,500 healthy human subjects across 10 countries (r = 0.86; (Kirsch-Volders et al., 2014; Ceppi et al., 2010), suggesting that increases in PBL genotoxicity are relevant to human URT cancer risk, although the magnitude of MN induction in buccal cells is typically less than in PBLs (Holland et al., 2008). Elevated PBL MN and nuclear bud incidence, such as that observed in cohorts of formaldehyde-exposed workers, are predictive for lung cancer risk in smokers (Fenech et al., 2011; El-Zein et al., 2006) and are associated with increased cancer incidence in otherwise healthy individuals (Kirsch-Volders et al., 2014; Holland et al., 2008; El-Zein et al., 2006; Bonassi et al., 2008); see Section 3.3.3 Evidence on Mode of Action). Parallel increases in buccal and PBL MN incidence have also been observed in human workers chronically exposed to wood dust, another URT carcinogen (Rekhadevi et al., 2009). Similarly, in radon-exposed miners, a 1% increase in the frequency of aberrant PBLs was associated with a 60% increase in lung cancer risk (Smerhovsky et al., 2001; Smerhovsky et al., 2002). Together, this evidence supports associations between local and peripheral clastogenicity and between tissue clastogenicity and human respiratory carcinogenesis.

The mutation profile of formaldehyde-induced rodent tumors has not been well characterized, and it is unclear which of the various genotoxic endpoints elicited by formaldehyde exposure may lead to permissive mutations in either rodent or human URT carcinogenesis. P53 mutations were specifically evaluated in SCCs isolated from the nasal passages of F344 rats following 2 years of exposure to 18 mg/m^3^ formaldehyde (Wolf et al., 1995a; Recio et al., 1992), and in hyperplastic nasal tissues following 90 days of exposure to similar concentrations (Meng et al., 2010). While not detected in hyperplastic epithelium, the p53 mutations at codon 271 detected in five of the 11 rat URT SCCs have also been described in human URT cancers (Wolf et al., 1995a; Recio et al., 1992; Hollstein et al., 1991; Audrezet et al., 1993). At 18 mg/m^3^, nasal squamous metaplasia preceding or concomitant with hyperplasia is significantly elevated early after first exposure (within 7 days; see Section 3.2.4), prior to the emergence of dysplasia at 365 days, in the nasal regions of F344 rats, which eventually harbor SCC after 330−548 days (Monticello et al., 1996; Kerns et al., 1983; Kamata et al., 1997). The absence of p53 mutations in reactive nasal mucosa after 90 days of exposure is consistent with p53 mutations acting as a selective or permissive factor acquired during the latter stages of formaldehyde-initiated carcinogenesis, facilitating increased genetic instability and the progression of nascent neoplasms to SCCs, which emerge months later (Hanahan and Weinberg, 2000, 2011). Perhaps consistent with this potential temporal relationship, a recent study of short-term (i.e., 8-week) exposure to high levels of formaldehyde in two strains of p53 deficient mice failed to observe any treatment-related increases in nasal tumors at 32 weeks post-exposure, despite pronounced metaplasia (Morgan et al., 2017). Additional study using longer-term exposures, ideally in rat models (as mice are demonstrably less sensitive), would help clarify the role of p53 in URT carcinogenesis.

The proportion of human URT SCCs exhibiting p53 mutations is similar to that reported in formaldehyde-elicited rat URT SCC (~45%), and codons orthologous to those with mutations in rat nasal SCC are also mutated in human URT SCC (Catalogue of Somatic Mutations in Cancer [COSMIC] build v73; filters: upper aerodigestive tract, all subtissues, carcinoma, squamous cell; accessed 10 July, 2015; http://cancer.sanger.ac.uk/cancergenome/projects/cosmic/). However, this has not been examined specifically in formaldehyde-exposed humans. The observation that formaldehyde-induced rat URT carcinomas share similar p53 mutations with cancers in analogous human tissues suggests that rat and human URT tissues may be subjected to similar initiating or selective biological processes, which further supports the relevance of rodent URT tumors in informing human cancer risk.

###### Summary

Genotoxicity in the respiratory or transitional epithelium temporally and dose-responsively precedes and anatomically coincides with sites of significant SCC and PA induction (see above synthesis of the animal evidence) in rats following chronic formaldehyde exposure as a function of increasing concentration (NTP, 2010; Liteplo and Meek, 2003). In both rats and nonhuman primates, nasal DPX and exogenous formaldehyde N_2_-hmdG adducts were elevated in an exposure concentration- or duration-related manner after 1−28 days of experimental exposure to formaldehyde concentrations ≥ 0.9 mg/m^3^ within the range of average occupational exposures associated with increased DPXs in human PBLs (0.5−4 mg/m^3^) after various durations of exposure (see Appendix C.3) and increased MNs in human nasal (0.1−1 mg/m^3^) or buccal tissue (0.2−0.5 mg/m^3^) after ≥5 years (Appendix C.3). Human mortality risks from nasopharyngeal cancer were also elevated with both increasing exposure concentration and duration, with elevated risks evident at concentrations ≥1.23 mg/m^3^ and after ~20 years following first exposure (see above synthesis of the human evidence). The coherence of strong and consistent evidence for genotoxicity spans multiple evidence types from exposed humans to relevant model systems and species, in analogous POE and surrogate tissues, incorporating pertinent aspects of dose-response and temporality (i.e., preceding other mechanistic events), all of which strongly supports a role for direct DNA damage leading to mutagenicity in formaldehyde-induced URT carcinogenesis.

###### Cellular proliferation

Studies employing labeled nucleotides or analogs have reported increased epithelial cell proliferation in the nasal and extranasal passageways of rhesus monkeys after 7 or 42 days of exposure to 7 mg/m^3^, concurrent with increased tissue hyperplasia and metaplasia in the nasal epithelium, nasopharynx, and larynx (see Section 3.2.4 and Appendix C.7.1). Acute exposure (1−9 days) to similar concentrations also stimulated epithelial proliferation in the anterior nasal passages of F344, Wistar, and Sprague Dawley rats, while only exposures to ≥15 mg/m^3^ increased proliferation in similar tissue from B6C3F_1_ mice. This difference in exposure concentrations required to induce proliferation in nasal epithelium across rodent species may result from the increased reflex bradypnea observed in mice compared to similarly exposed rats. Respiratory minute volumes of mice acutely exposed to 15−18 mg/m^3^ decrease such that they are roughly equivalent to a 7 mg/m^3^ exposure in rats (see Appendix C.2) (Swenberg et al., 2013). This difference in rodent physiology between mice and rats is also consistent with the reported SCC incidence of 1−2% following chronic exposure to 18 and 7 mg/m^3^, respectively (see above synthesis of the animal evidence), and with the apparent resistance of mice to formaldehyde-elicited cytotoxic nasal pathology (see Section 3.2.4).

In general, the exposure level marking increased proliferation was inconsistent across studies (see Appendix C.7.4 and the quantitative “Characterization of uncertainty and variability in cell replication rates” in Appendix D.2.2); in some cases, as discussed under “Biological plausibility of alternate assumptions” in Appendix D.2.2, the cell proliferation data appear to be more representative of a monotonic increasing dose response without a threshold. In Wistar rats, proliferation was increased in the anterior nasal passages after 28 or 90 days of exposure with an LEC of 4 mg/m^3^, a concentration not frequently evaluated in other species (see specific evaluations of proliferation in Appendix A.5.6) (Zwart et al., 1988; Wilmer et al., 1987, 1989). In F344 rats, cellular proliferation was induced to a similar extent after 90 days at ≥12 mg/m^3^ (Monticello et al., 1996; Andersen et al., 2010) or 7 mg/m^3^ in some studies (Casanova et al., 1994). A lesser magnitude of proliferation was also apparent following exposure to ≥3 mg/m^3^ (Monticello et al., 1996; Meng et al., 2010; Andersen et al., 2010). In both strains, some evidence supports that increases in proliferation may occur at 0.8–2.5 mg/m^3^ (Zwart et al., 1988; Meng et al., 2010; Casanova et al., 1994; Andersen et al., 2010). While proliferation in the anterior nasal passages may appear to be stimulated to a greater extent at slightly lower exposure levels in Wistar versus F344 rats (due in part to choice of exposure concentrations evaluated), the strain sensitivity to nasal SCC induction was reversed: nasal tumors were present in only 4% of Wistar rats after 28 months of exposure to 12 mg/m^3^, while 22% of F344 rats developed tumors after 24 months of exposure to the same concentration ((Woutersen et al., 1989; Monticello et al., 1996). This pattern also appears in PA incidence, where PAs were reported in ~1% (1 rat) of Wistar rats exposed to 11 mg/m^3^ for ≤28 months (with lifetime observations), versus 6% of F344 rats exposed to 12 mg/m^3^ for 24 months (Woutersen et al., 1989; Monticello et al., 1996; Feron et al., 1988). Unlike the differences seen with Wistar rats, incidence of both nasal SCCs and PAs appear to be generally similar between Sprague Dawley and F344 rats exposed to 18 mg/m^3^ for 24−28 months, although the limited evidence in Sprague Dawley rats precludes a comparison of URT proliferation with F344 rats following repeat exposure (see above synthesis of the animal evidence). While limited, the available data suggest that some strain differences exist in the URT tumor response in Wistar versus F344 rats, while proliferation appears to be similarly induced in both rat strains.

Integrating across all available studies, the magnitude of proliferation induced in F344 rats was generally similar following exposure durations of 4−90 days (see Appendix C.7.1). In the single study available reporting URT epithelial proliferation in rats following chronic as well as subchronic exposures, the proliferation response declined between 45 and 90 days, most strikingly at 7 mg/m^3^, and then decreased gradually throughout 548 days of continuous exposure (Monticello et al., 1996). An inverse association between nasal epithelium DNA synthesis and exposure duration was reported between 7 and 42 days of exposure in rhesus monkeys (Monticello et al., 1989), suggesting that a proliferative peak may have been reached fairly rapidly in primates (≤7 days).

Investigations into the relative mitogenic versus cytotoxic consequences of formaldehyde exposure in vitro have revealed that while significant cytolethality was observed at >1 mM in cultured human colon carcinoma (HT-29), T lymphocyte (Jurkat E6-1) and umbilical vein endothelial cells (HUVEC) (Tyihák et al., 2001; Saito et al., 2005), lower and more physiologically relevant dose levels (0.1 mM) induced proliferation in both HT-29 and HUVEC cells, and to a greater extent in the neoplastic HT-29 cells compared with the nonneoplastic HUVEC (Tyihák et al., 2001). However, ≥0.1 mM induced endoplasmic reticulum (ER) stress and increased the ratio of proapoptotic to antiapoptotic markers in both human lung carcinoma (A549; (Lim et al., 2013) and lymphoblast cell lines, with greater sensitivity observed in DNA repair deficient cells (Ren et al., 2013) (see Appendix C.3 and C.7). Increased sensitivity to formaldehyde-induced cell death has been consistently reported in eukaryotic cell lines deficient in excision, DNA crosslink, or chromosomal breakage repair (Rosado et al., 2011; Ridpath et al., 2007; Ren et al., 2013; Noda et al., 2011; Mchale et al., 2014; de Graaf et al., 2009), suggesting that unresolved genotoxicity could contribute to some of the cytotoxicity observed with increasing levels of formaldehyde exposure. Formaldehyde-stimulated cell cycle progression may be highly context dependent and only observed in circumstances where the concomitant genotoxicity and low-level toxicity (e.g., ER stress) are adequately controlled. This variable proliferation response in vitro is consistent with some in vivo observations of increased epithelial proliferation in the nasal passages of F344 rats following subchronic exposure at subcytotoxic exposure levels (~0.8−3 mg/m^3^; see Section 3.2.4 and specific proliferation analyses in Appendix C.7.1 and Appendix D.2.2). However, nasal epithelial proliferation in the absence of cytotoxic nasal pathology was not consistently observed, and cell-density adjusted cellular proliferation indices correlate well with tumor formation following chronic exposures to ≥7 mg/m^3^, concentrations that induced significant epithelial pathology in rodent nasal passages (see Section 3.2.4).

###### Summary

Nasal epithelial cell proliferation was positively associated with the induction of squamous metaplasia and necrosis or epithelial erosion in F344 rats (Andersen et al., 2010) and correlated with SCC incidence as a function of both anatomical location and exposure concentration following exposures ≤19 mg/m^3^ for up to 548 days (Swenberg et al., 2013; Monticello et al., 1996). The association between chemical carcinogenicity and epithelial cell proliferation has been described for several respiratory tract carcinogens and rodent models of human cancers (Monticello et al., 1993). Such a relationship can accelerate the acquisition of traits consistent with a current understanding of the carcinogenic process (Sonnenschein and Soto, 2013; Hanahan and Weinberg, 2011; Goodson et al., 2015), as exemplified in the well-described etiology of mutagen-induced rat mammary gland tumorigenesis (Russo et al., 1990). The available data suggest that formaldehyde may elicit some mitogenicity at low-to-moderate exposures through an unknown cellular mechanism independent from the regenerative tissue proliferation associated with cytotoxicity following exposure to higher concentrations (see Figures 3-24−3-26). However, the evidence supporting proliferation as an effect independent from cytotoxic tissue pathology is not strong or consistent as the evidence supporting regenerative proliferation in response to cell death; furthermore, while the database contains several reports evaluating cellular proliferation at a molecular level (i.e., DNA nucleotide analog incorporation), it suffers from a dearth of molecular evaluations on other cellular functions, such as markers of toxicity, cell cycle regulation, or death, which prevents a more precise delineation of mitogenic effects at a cellular level from compensatory proliferation at a tissue level.

###### URT cytotoxicity, pathology

In humans, nasal airway function may be impaired at average exposures as low as 0.01 mg/m^3^, suggesting that pathological URT changes occur even at low exposures (see Table 3-42) (Norback et al., 2000), while increasingly severe nasal histopathology (including hyperplasia, keratinization, and metaplasia) is associated with average chronic exposures ≥0.3 mg/m^3^ (see Table 3-42) (Odkvist et al., 1985; Holmstrom et al., 1989c; Edling et al., 1988; Boysen et al., 1990; Ballarin et al., 1992). The incidence of distinct dysplasia, a dedicated preneoplastic lesion, was elevated in study participants with higher average chronic exposure, ranging from 0.1 to 3 mg/m^3^ (see Section 3.2.4). Human nasal and throat irritation and cytotoxicity was positively associated with exposure concentrations ≥0.2 mg/m^3^ in controlled acute exposure trials or after a single 8-hour work shift (see Table 3-42) (Priha et al., 2004; Kulle et al., 1987) and average exposure to 0.05−1 mg/m^3^ in occupational cohort studies (Horvath et al., 1988; Holness and Nethercott, 1989). Consistent with these observations, fluctuation in ciliary beat frequency was also reported in primary human nasal cells exposed to 0.5−3 mg/m^3^ following differentiation into a functional ciliated epithelium and cultured on an air-liquid interface (ALI) in vitro (Wang et al., 2014b). However, unlike the positive association between human MN induction and exposure duration, or the clear relationship between rat squamous metaplasia induction and formaldehyde exposure duration (see Section 1.2.4), no significant associations were reported between exposure duration and various indications of human nasal mucosal pathology (see Table 3-42).

Similar to observations following chronic human exposure, the incidence of squamous metaplasia and hyperplasia in the nasal turbinates of cynomolgus monkeys was also positively associated with exposure concentrations ≥1 mg/m^3^ (Rusch et al., 1983). Although lesion severity in rhesus monkeys was positively associated with extending exposure duration from 7 to 42 days at 7 mg/m^3^ (Monticello et al., 1989), this observation is not necessarily discordant with the human data set, which generally evaluated pathology resulting from chronic durations as a function of differences in years of exposure versus days, as was evaluated in the nonhuman primates. Nonhuman primates may be more resistant to nasal irritation and cytotoxicity than humans, as squamous metaplasia and hyperplasia were observed following 42 days exposure to 7 mg/m^3^ in rhesus monkeys (Monticello et al., 1989), or 180 days of exposure to 4 mg/m^3^ to cynomolgus monkeys, with 1 of 6 monkeys affected at 1 mg/m^3^ (vs. 0/12 in controls), and no effects observed at 0.2 mg/m^3^ (Rusch et al., 1983), although no studies have evaluated exposure durations directly analogous to chronic human exposure.

In F344 rats, nasal mucociliary function and flow rate decreased in an exposure concentration- and duration-associated manner following acute exposures to ≥3 mg/m^3^ (Morgan et al., 1986a; Morgan et al., 1986c). Incidence or severity of squamous metaplasia also increased in both a duration- and concentration-dependent manner following exposures ≥3 mg/m^3^ (Kerns et al., 1983); all effects were inversely associated with increasing distance from the apical POE (Casanova et al., 1994). Nasal pathology in Wistar rats was positively associated with exposure concentration, but not cumulative exposure, following subchronic exposures (Wilmer et al., 1987, 1989). This result is consistent with similar relationships reported between DNA synthesis rates and exposure concentration in the same anatomical regions (i.e., Level II) in both Wistar and F344 rats (see Table 3-42) (Zwart et al., 1988; Wilmer et al., 1987, 1989; Swenberg et al., 1986). Generally, formaldehyde exposure elicited similar pathology and ultrastructural changes in the analogous nasal passages of both nonhuman primates and rats (see Section 3.2.4). F344 rats appear to be similarly sensitive to the onset of nasal cytotoxicity induced by chronically inhaled formaldehyde compared with nonhuman primates, since a similar duration of exposure (180−365 days) induced nasal squamous metaplasia or hyperplasia in both species at ≥3 mg/m^3^, while higher concentrations of ≥7−12 mg/m^3^ were generally required to induce similar pathology following shorter durations (30−90 days; see Table 3-42). However, nasal damage in nonhuman primates (rhesus monkeys) became more developed, covered the URT epithelium to a greater extent, progressed to posterior nasal regions, and involved the larynx/trachea in less time (1.5 months) and at lower exposure levels (Monticello et al., 1989) than similar changes observed in rats (Kerns et al., 1983). Likewise, nasal squamous metaplasia in cynomolgus monkeys was detected in all animals exposed to 4 mg/m^3^ after 6 months (Rusch et al., 1983), while a comparable prevalence of analogous pathology in F344 rats required exposure to 18 mg/m^3^ and ≥18 months to develop (see Section 3.2.4).

Other rodent species appear to be less sensitive to formaldehyde-induced nasal dysplasia, SCC and PA (in order of decreasing sensitivity): F334 and Sprague Dawley rats > Wistar rats > B6C3F1 mice > hamsters (see synthesis of animal evidence in this section). Necrosis, inflammation, hyperplasia, or squamous metaplasia were observed in the anterior nasal passages of F344 rats, Wistar rats, and B6C3F_1_ mice after short-term high-concentration exposures, as well as in the posterior nasal cavity of F344 rats after 6 months, and in the larynx/trachea after 18 months of exposure to 18 mg/m^3^, although tumors of the larynx or trachea have not been associated with formaldehyde exposure in rodents (see Section 3.2.4). Conditions that induced nasal dysplasia in rats and mice consistently resulted in SCC formation after an additional 6−12 months of exposure, whereas neither dysplasia nor SCCs were observed in hamsters. While formaldehyde-associated benign PAs and malignant SCCs may share similar tissue level origins (i.e., the transitional or respiratory but not olfactory epithelium), this reflects a neoplastic fate arising from morphologically different epithelial populations and does not imply that PAs are precursor lesions to SCC. In the rodent nasal cavity, SCCs are thought to arise directly from hyperplastic or dysplastic tissue (i.e., atypical squamous metaplasia) and do not necessarily progress through a benign tumor intermediate (McConnell et al., 1986).

###### Summary

Progressive tissue cytotoxicity and induction of proliferative pathological lesions in the URT respiratory or transitional epithelium temporally and dose-responsively precede and anatomically coincide with sites of significant SCC and PA induction (see Section 3.2.4) in rats following chronic formaldehyde exposure as a function of increasing concentration (NTP, 2010; Liteplo and Meek, 2003). Similar lesions were also observed in the URT of nonhuman primates exposed up to 180 days, which appeared to progress farther along the primate respiratory tract. In humans, some indications of URT cellular toxicity have been reported at very low concentrations, with hyperplasia, keratinization, and metaplasia observed following chronic exposures ≥0.3 mg/m^3^, which are concentrations approximately 10-fold lower than those eliciting similar effects in experimental animal models. Together, strong and consistent evidence exists associating URT epithelial pathology-driven tissue proliferation with SCC induction in rodent experimental models. Along with limited information from both nonhuman primates and occupationally exposed humans, these observations support a significant role for regenerative tissue proliferation in URT carcinogenesis associated with formaldehyde exposures high enough to induce cytotoxic URT pathology. However, the evidence from animal studies indicates uncertainty regarding the exposure concentration at which this proliferation occurs (see Figure 5-6).

##### Summary of evidence supporting the primary mechanistic considerations

In F344 rats chronically exposed to formaldehyde, there is a clear temporal, dose-responsive, and biological relationship in the appearance of exposure-related genotoxicity, sustained epithelial damage, cellular proliferation, and eventual SCC or PA development, consistent with similar relationships evident in analogous URT tissues from both the nonhuman primate and human databases. Furthermore, the chronic formaldehyde exposure concentrations reported to elicit nasal cytotoxic pathology appear to be higher in the rats and nonhuman primates evaluated experimentally (≥3 mg/m^3^), compared with the results from human epidemiological cohorts (≥0.3 mg/m^3^; see Table 3-42), whereas formaldehyde-associated genotoxicity has been induced in analogous POE tissues from rats, nonhuman primates, and humans exposed to similar formaldehyde concentrations (see Table 3-42). Together, genotoxicity, cellular proliferation, and cytotoxicity-induced tissue regenerative proliferation exhibit multiple layers of coherence as a function of species and anatomy, temporality, concentration, and duration of exposure. When integrated, this evidence forms a biologically relevant MOA for formaldehyde exposure-induced URT carcinogenesis (U.S. EPA, 2005a).

##### Other factors modifying the mode of action

###### Oxidative stress, immune disease, and dysfunction

Increased rhinitis, nasal irritation, URT inflammation, and some indications of increased oxidative stress were observed in human cohorts after environmental or occupational exposures at the lower end of the range of average formaldehyde exposures associated with nasal hyperplasia and metaplasia. Rhinitis has been observed following subchronic or longer exposure in F344 rats and B6C3F1 mice, as well as chronically exposed human workers, and some observations suggest that oxidative stress may in part evolve as an effect secondary to the activation of inflammatory leukocytes in the human respiratory tract (see Section 3.2.3 and Appendix C.7). The prevalence of allergic conditions and asthma symptoms are increased in both children and adults exposed to formaldehyde, suggesting that immune dysfunction occurs to some extent in respiratory tract tissues following formaldehyde exposure (see Section 3.2.3). These observations may imply a decreased functional activity of immune effector cells. Whether these effects are due to immunosuppression, inappropriate polarization, or exposure-related cytotoxicity, such immune dysfunction could promote a chronic inflammatory environment and permit cancer progression (Mantovani et al., 2008; Jia et al., 2014; Coussens et al., 2013a, b; Balkwill et al., 2012).

In experimental rodent studies, depletion of nonprotein sulfhydryls (NP-SH, primarily GSH) increased DPX formation in the nasal mucosa of F344 rats following formaldehyde exposure to >1 mg/m^3^ (Casanova and Heck, 1987), while GSH coadministration attenuated increases in DPX formation in systemic tissues from formalin-exposed BALB/c mice [Ye et al. (2013a); see also Appendix C.3 and C.7]. Although alterations in cellular GSH content may affect DPX formation and the mutagenic potential of formaldehyde exposure, it is unclear whether formaldehyde exposure itself will reduce URT glutathione levels in rodents. For example, even though glutathione reductase activity was decreased in the rat URT following short-term exposure to ≥4 mg/m^3^, total non-NP-SH content actually increased (Cassee et al., 1996). A few other rodent studies have reported increased oxidative stress from the lower respiratory tract (LRT) following short-term exposures; however, data on oxidative stress endpoints from evaluation of URT tissues is limited, and it remains unclear whether LRT responses indicate analogous responses in URT passages (see Appendix C.7). In vitro, cellular GSH concentration was inversely correlated with formaldehyde cytotoxicity in human oral fibroblast cells and rat hepatocytes (Nilsson et al., 1998; Ku and Billings, 1984). In conditions where GSH was sufficiently decreased, formaldehyde inhibited mitochondrial respiration and led to increased lipid peroxidation and ROS production (IARC 88; (Teng et al., 2001), which could trigger NF-κB activation (Zhang et al., 2013a) and thus initiate an inflammatory signaling cascade. While formaldehyde may directly deplete cellular GSH pools to some extent, the resulting impact on cellular cytotoxicity can be amplified by other sources of oxidative stress (Saito et al., 2005). Taken together, formaldehyde exposure may exacerbate oxidative stress primarily resulting from inflammation, cytotoxicity, or sulfhydryl depletion, which could further augment DPX-mediated genotoxicity as well as increasing ROS-mediated genetic instability and cell death. This could result in an amplification of both direct and indirect mutagenicity in the nasal epithelium.

Tumor immunosurveillance may play an important role specifically in limiting human nasopharyngeal carcinoma development; for example, patients with acquired immune deficiency syndrome (AIDS) are at significantly higher risk of developing both nonkeratinizing (commonly associated with Epstein-Barr virus [EBV] infection) as well as keratinizing nasopharyngeal carcinoma (Shebl et al., 2010). In vitro, formaldehyde attenuates the perforin secretion and cell lytic activity of cultured mouse and human natural killer (NK) cells at subcytotoxic concentrations (Li et al., 2013b; Kim et al., 2013a), which would limit NK-mediated destruction of infected epithelial cells and prolong URT infection, possibly inhibiting any tumor-suppressive function of these cytotoxic lymphocytes. Consistent with this theory, 2 weeks of formaldehyde exposure attenuated both NK cell numbers and activity in the lungs of both naïve and tumor-bearing mice. This attenuation was associated with enhanced malignancy, growth, and neutrophil involvement of lung metastases formed by injected syngeneic melanoma cells (Kim et al., 2013a). Additional evidence for other formaldehyde-induced immune dysfunction comes from allergic sensitization studies and reports of exacerbated immune-mediated airway hyperresponsiveness presensitized rodents (see [underlined: Section 1.2.3]). Further, evidence exists to suggest the possibility that formaldehyde exposure may alter immune cell phenotypes, maturation, and survival at a systemic level (see relevant mechanistic discussions in Sections 3.2.3 and 3.3.3); however, few studies have examined such evidence specifically within respiratory tissues, and those testing endpoints that might otherwise be most informative to this possibility (Zhao et al., 2020a) had methodological limitations that prevent clear interpretation. Together, however, the available data suggest that formaldehyde exposure may induce immune suppression or dysfunction in both experimental animals and humans, which could reduce the effectiveness of local immunosurveillance in suppressing tumor progression and metastasis, thus enabling URT carcinogenesis (Hanahan and Weinberg, 2000, 2011).

In summary, nasal infection and allergic symptoms are exacerbated in humans following exposure to fairly low formaldehyde levels, concomitant with or preceding epithelial tissue distress, inflammation, and preneoplastic lesion formation. Chronic inflammation is highly relevant to and positively associated with human risk of respiratory tract cancers; however, the specific mechanistic relationships between formaldehyde-induced inflammation, immune dysfunction, infection, allergy, oxidative damage, and URT cancer remain unclear.

###### DNA repair inhibition

The primary effects of formaldehyde interactions with DNA are N^2^-hmdG adducts, DPXs and DDCs, and strand breaks, and repair of such formaldehyde-mediated genotoxicity appears to be crucial to cell survival. Consistent with this hypothesis, DNA repair genes are rapidly induced in rat nasal mucosa following acute or subchronic exposure in vivo (Rager et al., 2014; Hester et al., 2005; Andersen et al., 2008) and human B-lymphoblastoid cells in vitro (Kuehner et al., 2013).

The primary mechanism for repair of N^2^-hmdG adducts is unclear. While nucleotide or base excision repair (NER/BER) may be responsible, the removal of small DNA adducts species may also result from nonspecific cellular processes (Lindahl, 1993; Brooks and Zakhari, 2014). The existence of two phases in the elimination of formaldehyde N^2^-hmdG adducts from the rat nasal mucosa in vivo also supports a role for multiple removal mechanisms (Swenberg et al., 2013). DPXs are unlikely candidates for direct removal via excision repair in mammalian cells, although a fraction of smaller crosslink products (likely DDCs) may be removed via NER activity or proteolysis (see Appendix C.3 and C.7 for detailed discussions). DPXs are more likely repaired via activity of the BRCA/Fanconi anemia family (FANC) proteins, components of the homologous recombination repair pathway, which regulate DPX repair following chronic or lower formaldehyde concentrations in mammalian cells and can attenuate the formation of DSBs and some chromosomal abnormalities (see Appendix C.3) (Rosado et al., 2011; Ren et al., 2013; Nakano et al., 2009). If unresolved, DPXs could lead to SSBs, DSBs, various cytogenetic abnormalities, and genomic instability (Ridpath et al., 2007; Ren et al., 2013; Noda et al., 2011; Nakano et al., 2009; Langevin et al., 2011; Kumari et al., 2015; Kirsch-Volders et al., 2014; Brooks and Zakhari, 2014). Additionally, DNA repair pathways are differentially engaged as a function of damage location in relation to DNA replication machinery, supporting a role for the context of DNA damage in determining the manner of its resolution (de Graaf et al., 2009).

In cultured human fibroblasts, exogenous formaldehyde directly interfered with DNA-binding damage sensor complex recruitment to DNA adducts and inhibited the repair of DNA lesions induced by either ultraviolet light or cisplatin adduction (Luch et al., 2014), consistent with similar observations in other human tissues and cells (see Appendix C.3 for a detailed discussion). This interaction also inhibited the migration and function of BER, and consequently inhibited the repair of oxidative DNA lesions. These results suggest that formaldehyde may inhibit excision repair by directly interfering with the DNA damage detection apparatus, which could delay the recognition and repair of DNA damage induced by both formaldehyde as well as other agents. However, any direct impact on the BRCA/FANC-mediated DNA repair pathway, which is likely to be responsible for removing formaldehyde-induced DPXs following chronic exposure, remains to be elucidated.

Members of the X-ray repair cross-complementing gene (XRCC) family serve as scaffolding proteins for the repair of single- and double-strand DNA breaks, including those caused by oxidative or UV-induced DNA damage (Kirsch-Volders et al., 2014). Despite several correlations between XRCC polymorphisms and increased sensitivity to formaldehyde-induced genotoxicity in human tissues and cells, the role for XRCC family proteins in regulating formaldehyde mutagenicity remains unclear (see Appendix C.3 for a detailed discussion). The molecular mechanisms by which formaldehyde causes MN are also unknown, but incomplete repair of DNA-protein or DNA-DNA crosslinks, and the consequent stress from stalled replication forks, could result in DNA strand breaks and possibly centromere-negative MN formation (Nakano et al., 2009; Kirsch-Volders et al., 2014; Brooks and Zakhari, 2014). Taken together, the available data suggest that formaldehyde exposure may inhibit the detection and repair of lesions resulting directly from formaldehyde-DNA interactions, as well as genotoxicity resulting from other sources, and may thereby accelerate tissue carcinogenesis by exacerbating both direct and indirect mutagenesis. However, the available data are insufficient to determine any independent contribution of such interference in DNA repair to URT carcinogenesis.

###### Epigenetics and toxicogenomics

Changes in message RNA (mRNA) transcript levels from pathways relevant to URT carcinogenesis (e.g., cell cycle, proliferation signaling, apoptosis, and DNA repair) have been reported in URT tissues following formaldehyde exposure, possibly mediated by microRNA (miRNA) regulation, changes in DNA/histone modifying marks including methylation, acetylation and formylation, or by responses to cellular toxicity and tissue distress (see Appendix C.7 for a detailed discussion). After repeated exposure, mRNA levels for genes involved in growth signaling pathways increased in a concentration- or duration-related manner in F344 rats (Rager et al., 2014; Andersen et al., 2010), and some of these pathway perturbations were also reported in nonhuman primates (Rager et al., 2013).

In nasal tissues from acutely exposed nonhuman primates, significant induction of miR-125b and suppression of miR-29a were observed (Swenberg et al., 2013; Rager et al., 2013). Expressions of several candidate mRNA targets of miR-125b were also decreased in this study, consistent with miR-125b induction, including two that were also reported to be affected in subchronically exposed rats (Andersen et al., 2010) (see Appendix C.7). In analogous rat nasal tissues, expression of several members from the growth-suppressing miRNA family let-7 decreased following subchronic exposure (Rager et al., 2014), consistent with observations from exposed A549 lung carcinoma cells (Rager et al., 2011). Decreased expression of let-7 family members was found in nasopharyngeal carcinomas compared with healthy tissue (Li et al., 2011), and this effect has been reported to promote proliferative and oncogenic cellular signaling pathways in respiratory tract cancers (Jakopovic et al., 2013). Despite the numerous significant changes in miRNA expression levels reported following formaldehyde exposure, miR-203 was the only target reported to be similarly affected (decreased) in analogous nasal tissue from both rats and nonhuman primates (Rager et al., 2013; Rager et al., 2014) (see Appendix C.7). Overall, changes in expression of these miRNAs are generally consistent with observations in human lung, prostate, breast, and bone marrow cancers (Ma and Weinberg, 2008; Garzon et al., 2009; Fabbri et al., 2007). The abundance of highly significant changes in specific targets within individual arrays or experiments, but limited concordance across expression array data sets or species, is not unusual; however, it greatly complicates interpretation and integration of various data streams (Weinberg, 2014).

DNA methylation and histone modification can promote carcinogenesis through steric regulation of enhancer/promoter binding and transcription factor-DNA association, thereby affecting gene transcription (Vaissière et al., 2008). DNA methylation was globally decreased in human bronchial epithelial cells exposed to formaldehyde in vitro for up to 24 weeks, which may have been mediated by the down-regulation of de novo methyltransferase genes (Liu et al., 2011b). Formaldehyde may affect gene transcription via posttranslational modification (PTM) of histone proteins, in part by directly adducting unmodified lysine residues in histones to form N^6^-formyllysine, thus preventing acetylation of this residue (Lu et al., 2008; Edrissi et al., 2013a). Such irreversible adduction could interfere with transcriptional activation, nucleosome organization (Wisniewski et al., 2008), and DNA lesion repair activity (Luch et al., 2014). Levels of these formylated lysine adducts increase in a concentration-dependent manner in the URT of rats exposed to ≥0.9 mg/m^3^ (Edrissi et al., 2013b), levels at which increased DPXs are also observed (see Table 3-39, and Appendix C.3). In addition, exogenous formaldehyde can induce histone phosphorylation through activation of MAP kinase signaling in vitro (Yoshida and Ibuki, 2014). In A549 cells, as histone serine phosphorylation increased, lysine acetylation levels correspondingly decreased, providing an additional (indirect) mechanism by which exogenous formaldehyde attenuates histone acetylation and potentially modulates gene transcription. c-Jun N-terminal protein kinase (JNK) was the primary regulator of this histone phosphorylation, which led to elevated nuclear c-Fos and c-Jun protein expression (Yoshida and Ibuki, 2014; Shi et al., 2014). Together, c-Fos and c-Jun comprise the transcription factor AP-1, which can play an early role in human respiratory tract carcinogenesis (Karamouzis et al., 2007). Likewise, increased histone phosphorylation may be an important mechanism specifically in human nasopharyngeal carcinogenesis (Li et al., 2013a), suggesting that these epigenetic effects may play a causal role in human URT cancer formation.

The existing evidence illustrates myriad time- and concentration-dependent effects following formaldehyde exposure, indicating the potential for both direct and indirect impacts on transcriptional activity, in addition to inhibiting protein translation via miRNA dysregulation. What is lacking, however, are conceptual paradigms and computational strategies for integrating systems and cancer biology data streams (Weinberg, 2014). While provocative, in the absence of direct hypothesis evaluation and more explicit phenotypic anchoring, the causal contribution of epigenetic effects to URT carcinogenesis cannot be evaluated independently from the primary mechanistic considerations outlined above.

##### Mode of action evidence integration and summary of analysis

Prolonged inflammation or irritation to the nasal mucosal surface has been associated with squamous metaplasia of the respiratory or transitional epithelium following exposure to infectious agents such as fungi or bacteria, but such exposures did not result in neoplasia (Monticello et al., 1990b; Brown et al., 1991). Likewise, chemical URT irritants such as dimethylamine, glutaraldehyde, ethylacrylate, hydrogen chloride, and chlorine gas cause rhinitis, inflammation, and cytotoxicity leading to squamous metaplasia or hyperplasia, but do not induce rat nasal tumors following chronic exposure (Wolf et al., 1995b; Sellakumar et al., 1985; NRC, 2014b; Mcgregor et al., 2006; Buckley et al., 1985; Albert et al., 1982). However, a number of genotoxic chemicals that also induce pathological changes in the rat nasal epithelium similar to formaldehyde (e.g., acetaldehyde, acrolein, 4-[N-methyl-N-nitrosamino]-1-[3-pyridyl]-1-butanone [NNK] and 1,2-epoxybutane) also induce nasal tumors including SCCs and PA-like lesions (Woutersen et al., 1986; U.S. EPA, 2003;NTP, 1988, 2011; Monticello et al., 1990b; Monticello et al., 1993). The comparison between formaldehyde and glutaraldehyde is particularly informative, as similar rat nasal cytotoxic pathology (e.g., squamous metaplasia, hyperplasia, inflammation) is elicited by exposure to both aldehydes (Hester et al., 2005), and yet glutaraldehyde exposure does not induce rat nasal tumors even after 24 months of exposure, while such tumors are induced following ≥12 months of formaldehyde exposure (Mcgregor et al., 2006). It has been proposed that glutaraldehyde exposure causes more epithelial cell death in the nasal mucosa compared with formaldehyde, possibly resulting in part from the greater inability of cells to repair or otherwise resolve any glutaraldehyde-DNA adducts (Mcgregor et al., 2006; Hester et al., 2005). The observation that a more effectively cytotoxic but less effectively mutagenic agent, glutaraldehyde, induces similar cytotoxicity-induced regenerative URT pathology to formaldehyde, yet appears unable to elicit rat URT tumors, suggests that cytotoxicity-induced regenerative proliferation alone is insufficient to induce URT carcinogenesis resulting from formaldehyde exposure.

The underlying balance between formaldehyde-associated cytotoxicity and genotoxicity may not only be responsible for the induction of these rare URT tumors in rats, but may also be key to the difference in phenotype between formaldehyde-induced nasal squamous metaplasia and that normally encountered in the aging rat. Gamma-glutamyl transpeptidase activity, present in normal and metaplastic epithelium in unexposed animals, is absent in the frequently atypical squamous metaplasia associated with formaldehyde exposure (Dinsdale et al., 1993; Brown et al., 1991). Such atypical squamous metaplasia (i.e., dysplasia) has been noted as a possible precursor to SCC in the rat URT (Monticello et al., 1990b). Together with the above, several lines of evidence converge to support the conclusion that while inflammation, squamous metaplasia, or hyperplasia alone are clearly not sufficient to induce nasal cancer in rats (Monticello et al., 1993), the amplified cellular proliferation occurring in regenerating tissues may be a mechanism by which genotoxicity-induced DNA mutation rates are augmented, facilitating neoplastic transformation. The marked increase in formaldehyde-initiated clones observed in vitro following growth stimulation by 12-O-tetradecanoylphorbol-13-acetate (TPA) in two-stage transformation studies (Ragan and Boreiko, 1981; Boreiko and Ragan, 1983) is also consistent with this conceptual model.

Strong and consistent evidence for formaldehyde-induced direct genotoxicity and mutagenicity comes from studies in mammalian cell lines, controlled inhalation studies in rodents and nonhuman primates, and occupationally exposed humans, wherein mutagenicity anatomically coincides with and temporally precedes URT tumorigenesis. Strong and consistent evidence associates URT tissue pathology of increasing severity and regenerative proliferation with squamous cell carcinoma (SCC) formation in experimental rodent studies at moderate-to-high exposure levels, consistent with some measurements of cytotoxicity reported in analogous nasal or buccal tissues from formaldehyde-exposed humans (see Table 3-43). Experimental evidence also links polypoid adenoma (PA) formation to formaldehyde exposure in several rat strains that also develop SCCs, and limited evidence associates increased PA incidence across a range of exposure concentrations in F344 rats. Limited evidence from a subset of experimental rodent studies also supports nasal epithelial cell proliferation in the absence of significant epithelial tissue pathology following acute, discontinuous, or moderate concentration exposure scenarios; however, while even intermittent proliferative stimuli could promote the growth of both nascent and malignant clones, the specific role for formaldehyde-induced cellular proliferation as an effect independent from either concomitant genotoxicity or tissue pathology remains undetermined. Evidence supporting the URT cancer MOA depends not only on temporality, duration, and concentration of exposure, but also anatomical location within the URT (i.e., incidence or severity of all primary mechanistic considerations decreases following an anterior-to-posterior gradient within the URT). While significant evidence supports some association between formaldehyde exposure and immune disease or dysfunction, including chronic inflammation and increased oxidative stress, the existing database is not sufficient to evaluate the independent contribution of these effects to URT carcinogenesis. Likewise, while formaldehyde appears to inhibit various cellular DNA repair pathways, the independent contribution of this effect to URT carcinogenesis remains to be determined.

Based on this detailed analysis conducted according to EPA’s cancer MOA framework (U.S. EPA, 2005a), there is sufficient evidence to conclude that formaldehyde induces URT carcinogenicity via at least two primary mechanistic considerations: genotoxicity-associated mutagenicity and cytotoxicity-induced regenerative proliferation. By means of its fundamentally mutagenic activity, formaldehyde damages DNA and increases the mutational burden of the URT mucosa when this damage is not adequately repaired, while mucosal cytotoxicity creates a tissue microenvironment driving continuous proliferation, facilitating the accumulation of mutations arising from both direct and indirect genotoxicity, thereby increasing the rate at which initiated clones are formed as well as stimulating the expansion of existing neoplastic colonies (see Table 3-43). The involvement of both mutagenicity and cytotoxicity-induced proliferation in the URT cancer MOA is strongly supported and internally consistent with the available formaldehyde evidence, and is also externally consistent with the described activities of other reported URT toxins and carcinogens.

Table 3-42 Summary considerations for upper respiratory tract (URT) carcinogenesis

Hypothesized mechanistic event | Experimental support for mechanistic event | Human relevance | Weight-of-evidence conclusion and biological plausibility
Direct genotoxicity and mutagenicity (see Table 3-39 and Appendix C.3) | - ↑ MN incidence in URT mucosa from human students and workers following subchronic-to-chronic exposure; - ↑ DPX and/or hmdG adducts in URT tissues of rhesus or cynomolgus monkeys, following acute exposure; - ↑ DPX or hmdG adducts and accumulation in URT tissues of F344 rats following acute to subchronic exposure; - No effect on MN incidence URT tissues of F344 rats follow subchronic exposure | Yes. Markers of direct genotoxicity correspond anatomically and temporally with subsequent URT neoplasia in experimental animal models, are consistent with increased MN induction following exposure in humans, and are presumed relevant to human carcinogenesis. | Strong and consistent evidence for formaldehyde-induced direct genotoxicity and mutagenicity exists from both experimental animal models and human molecular epidemiology to support a significant role for mutagenicity in URT carcinogenesis.
Cytotoxicity-induced regenerative proliferation (see Tables 3-40 and 3-41) | - ↓ Nasal mucociliary function, ↑ nasal hyperplasia, keratinization and/or squamous metaplasia, URT rhinitis, irritation, and inflammation in humans following acute to chronic exposure; - ↓ Nasal cilia content, ↑ hyperplasia and squamous metaplasia in URT tissues from monkeys following acute to subchronic exposure; - Associated with ↑ URT cell proliferation in rhesus monkeys; - ↓ Nasal mucociliary function, ↑ nasal rhinitis, hyperplasia and squamous metaplasia and/or dysplasia in various rat strains and B6C3F1 mice following acute to chronic exposure; - Associated with ↑ URT cell proliferation rats and mice | Yes. Increasing incidence or severity of URT dysfunction or pathology is positively associated with formaldehyde exposure in humans, nonhuman primates, and rats. A continuum of similar epithelial pathology is observed across affected species at POE tissues, and therefore the resulting increased cellular turnover observed in experimental models is presumed relevant to human carcinogenesis. | Strong and consistent evidence exists which associates the nasal epithelial pathology-driven proliferation with SCC abundance following formaldehyde exposure in rodent experimental models to support a significant role for regenerative proliferation in URT carcinogenesis.
Cellular mitogenesis in the absence of cytotoxic tissue pathology (see Table 3-41) | - Clear evidence of ↑ URT cell proliferation under conditions also resulting in tissue pathology in rhesus monkeys; - Exposure to subcytotoxic concentrations not evaluated; - Clear evidence of ↑ URT cell proliferation under conditions also resulting in tissue pathology in Wistar and F344 rats (≥4 mg/m^3^); - Suggestive evidence of ↑ URT cell proliferation under conditions not clearly causing tissue pathology (<4 mg/m^3^; see Appendix C.7) | Yes. Cellular proliferation may be increased at lower exposures and/or following shorter durations of exposure than that eliciting tissue pathology, which suggests that mitogenesis may be directly stimulated by formaldehyde exposure. Proliferation is expected to accelerate and enhance carcinogenesis in both humans and model systems, and is therefore presumed relevant to human carcinogenesis. | Limited and inconsistent evidence associates cellular proliferation with formaldehyde exposures below those eliciting cytotoxic pathology in the rat nasal epithelium, which precludes a determination as to the importance of this phenomenon in URT carcinogenesis.
Oxidative stress, immune disease and dysfunction in the URT (see Appendix C.7) | - ↑ LRT infection frequency, inflammation, allergic outcomes in children; ↑ leukocyte activation, allergy symptoms, chronic URT inflammation and ↓ infection resistance in adult workers following subchronic-chronic exposure; - ↑ LRT oxidative stress, markers of inflammation and leukocyte recruitment in rats and mice; ↑ airway wall thickening or remodeling in mice and rats following OVA sensitization; - ↑ Malignancy and neutrophil involvement of lung metastases, ↓ lung NK cell numbers and activity in C57BL/6 mice | Yes. Nasal infection, markers of persistent inflammation and/or immune dysfunction are positively associated with a range of formaldehyde exposure in both humans and rodents. Oxidative stress and chronic inflammatory diseases, including immunosuppression, are presumed relevant to human carcinogenesis. The relevance of other immune system dysfunctions to human carcinogenesis, such as allergy, is less clear. | While significant evidence exists supporting oxidative stress, chronic inflammation and various immune dysfunctions following formaldehyde exposure in humans and experimental animal models (see Appendix A.5.6), the evidence supporting associations between these effects and URT carcinogenesis is insufficient to evaluate the contribution of these effects independently in either humans or experimental animal models.

##### Summary of Inferences Regarding Mode of Action

###### Support for the hypothesized mode of action in experimental animal models

Strong, consistent evidence from rodent and nonhuman primate models supports the role for both direct (i.e., potentially DPX or hmDNA adduct-associated) mutagenicity, as well as indirect genotoxicity, mutagenicity, and regenerative proliferation resulting from respiratory tissue pathology, in rodent URT carcinogenesis. DNA labeling studies in rodent nasal epithelium suggest that cell division may also accelerate in response to marginally cytotoxic tissue concentrations resulting from short-term, lower level, or discontinuous exposure scenarios, although this evidence was neither strong nor consistent across similar studies and model systems. Observations of mutagenicity, cytotoxic epithelial pathology, and proliferation correspond histologically, anatomically, temporally, and dose-responsively with subsequent SCC and PA formation, consistent with contribution of both mutagenesis and regenerative proliferation to rodent URT carcinogenesis following formaldehyde exposure.

###### Relevance and applicability of the hypothesized mode of action to human cancer

Mutagenicity is presumed to be a relevant component of URT carcinogenesis in humans, supported by strong evidence of direct genotoxicity in both rodent and nonhuman primate experimental models and consistent observations of direct genotoxicity and mutagenicity from human epidemiological studies. Increased nasal epithelial cell proliferation (in rats and nonhuman primates) coincides anatomically with dysplastic lesions found in tissues from similar species, as well as with progressive, proliferative lesions in the nasal/buccal epithelium and nasopharynx of chronically exposed humans. This cross-species concordance, combined with the observation that cellular proliferation may be induced at lower exposures or following shorter durations of exposure than those eliciting tissue metaplasia, suggests that cellular proliferation in the presence of marginal tissue toxicity may also be potentially relevant to human URT carcinogenesis, as this episodic exposure scenario may be more frequently encountered in human populations than the continuous, chronic high-level exposures traditionally employed in rodent cancer bioassays. Increasing incidence or severity of nasal dysfunction and progressive pathology is associated with escalating formaldehyde exposure concentration or duration in humans, nonhuman primates, and rats. While POE tissue sensitivity to formaldehyde toxicity may quantitatively differ in humans versus rats and other rodents, qualitatively similar nasal dysfunction and pathology consistent with preneoplastic stages of cancer progression are observed across analogous tissues from all affected species, and therefore conclusions derived from these model systems are presumed relevant to human URT carcinogenesis. Given this presumed relevance, the potential for an increased susceptibility of specific human populations to developing URT cancers can be informed by both the human data and relevant mechanistic evidence from experimental model systems.

In general, URT findings in animals are found to be relevant to the URT cancer types and locations observed in humans despite significant differences in the occurrence of the individual cancer types. Firstly, site concordance is not required (U.S. EPA, 2005a). Secondly, the lack of a clear site-specific correspondence may be attributed to large interspecies differences in anatomy and airflow which in turn dictates formaldehyde distribution.

Regarding human NPC, the observed formaldehyde exposure-induced nasal tumors and mechanistic changes in animals are considered directly applicable to interpreting changes in the human nasopharynx. The nasopharynx is part of the nasal cavity and a recognized target of inhaled nasal toxicants across species (Chamanza and Wright, 2015).

Similarly, the URT MOA is considered relevant and applicable to the interpretation of human SNC, although some uncertainties remain. Across species, the sinuses are positioned close to the nasal cavity and encounter inspired air (Reznik, 1990). Analyses of sinonasal cancer cases indicate that most sinonasal cancers are squamous cell carcinomas (the primary tumor type in animals) and the upper nasal cavity is generally the primary site of tumor occurrence, in more than 40% of cases (the maxillary sinus is the next most common site), although it is often difficult to pinpoint the exact anatomical location from which the cancers developed (Turner and Reh, 2012; Llorente et al., 2014; Dutta et al., 2015). While these similarities support the relevance of the animal data to human SNC, it is necessary to consider the anatomy of the rodent and human URT given the importance of the distribution of inhaled formaldehyde and, as compared to the nasopharynx and other parts of the nasal cavity, a reduced flow of inspired air reaches sinonasal regions and the sinuses specifically (via narrow channels from the nasal cavity) (Xiong et al., 2008; Kumar et al., 2016). Although tumors in the sinonasal regions of exposed rodents or monkeys were not observed, this may be partially explained by differences in anatomy. Specifically, while humans have four paranasal sinuses, rodents and monkeys only have one, and the sinus in rodents is much smaller, thus presenting a smaller target for potential cancer development and a reduced capacity for detection as compared to in humans. Additional uncertainties in drawing interpretations across species include differences in airflow and tissue/cellular composition, which cannot be easily evaluated. Taken together, while there is some uncertainty in the applicability of the MOA to SNC, the mechanistic evidence (as well as the evidence on nasal cancers in animals) is interpreted as applicable to and supportive of human SNC.

The hypopharynx and oropharynx, and to a greater extent the larynx, are more distal from the POE than the nasopharynx and sinonasal tissues. Oronasal breathing in humans, as compared to nasal-only breathing in rodents, may suggest a greater relevance of tissue sites close to the oral cavity for human exposure; thus, mechanistic changes in rostral parts of the URT (i.e., the nasal cavity) in animals may be more relevant to human oropharyngeal cancer. In general, however, based on the known reactivity and distribution of inhaled formaldehyde, a greater level of uncertainty in the applicability of the animal nasal findings is inferred for these human cancer types, most notably laryngeal cancer, as compared to NPC or SNC.

###### Utility of mechanistic data for informing hazard quantification decisions

Since strong and consistent evidence supports the contribution of both direct genotoxicity and mutagenicity as well as cytotoxicity-induced regenerative proliferation as primary mechanistic considerations relevant to the pathogenesis of formaldehyde-associated URT cancer in rodents, mechanistic data relevant to these endpoints may be useful for informing quantification of nasal cancers in experimental animals following chronic formaldehyde exposure. In particular, quantitative evaluation of these mechanisms may inform a biological response basis for guiding dose-response extrapolations of rodent SCCs, as described in Section 5.2.1.

#### Evidence Integration Summary

Table 3-43 summarizes the evidence integration judgments and supporting rationale for the individual URT cancers.

Epidemiological findings provide robust evidence for nasopharyngeal cancers (NPCs), based on groups with occupational exposure. Consistent increases in NPC risk were reported by numerous high and medium confidence studies involving occupational exposure to formaldehyde among diverse populations in different geographic locations and exposure settings that accounted for expected temporal relationships for cancer induction and progression, with several reporting a large magnitude of relative risk (RR ≥3). A dose-response gradient was reported for various measures of exposure, including cumulative exposure, duration of exposure, and peak exposure. Robust evidence for nasal cancers is provided from studies in experimental animals (rats and mice). In animals, the incidence of lesions, as well as the tumor invasiveness and latency, was reproducibly shown to worsen with increasing formaldehyde exposure level. The distribution of tumors was dependent on duration of exposure as well as formaldehyde concentration. Mechanistic changes associated with the development of cancer in the nasal cavity were consistently observed in humans and experimental systems, including genotoxicity, epithelial damage and proliferation, and eventual cancer development in relevant URT tissues. The mechanistic changes and URT lesions exhibited a temporal and dose-response relationship coherent with carcinogenesis and supportive of a mutagenic MOA (see Evidence on MOA for upper respiratory tract cancers). The observed formaldehyde exposure-induced nasal tumors and mechanistic changes in animals are considered directly relevant to changes in the human nasopharynx (the nasopharynx is part of the nasal cavity and a recognized target of inhaled nasal toxicants). Thus, based on robust human evidence, robust animal evidence, and mechanistic evidence supporting a mutagenic MOA for NPC, the evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer in humans. This conclusion is primarily based on studies of groups exposed to occupational formaldehyde levels and coherent findings in animals, with tumors in rodents generally only observed at formaldehyde concentrations above 6 mg/m^3^.

Epidemiological findings also provide robust evidence for sinonasal cancer (SNC), based on groups with occupational exposure. The robust judgment for SNC is supported by a smaller set of epidemiological studies than for NPC, although a large, pooled analysis of 12 case-control studies included a large number of cases and greater detail on formaldehyde exposures, which increased confidence. This study observed an increasing trend in risk for adenocarcinoma with higher cumulative exposure among men and women in analyses that controlled for key confounders including exposure to wood dust. The studies were conducted in different geographic locations and exposure settings that accounted for expected temporal relationships for cancer induction and progression. Rodent nasal cancers and related mechanistic changes in the nasal cavity are considered relevant to human SNC (see discussion in Evidence on MOA for upper respiratory tract cancers), although some uncertainty in their applicability to SNC, as compared to NPC remains, and thus judgments of both robust and moderate animal evidence were considered. Ultimately, given this uncertainty in applicability, while the animal and mechanistic evidence cited for NPC is judged as informative and supportive for interpreting SNC, including providing sufficient support for a mutagenic MOA for this cancer type, the animal evidence overall is interpreted as moderate rather than robust. Based on robust human evidence, moderate animal evidence, and mechanistic evidence supporting a mutagenic MOA for SNC, the evidence demonstrates that formaldehyde inhalation causes sinonasal cancer in humans. This conclusion is primarily based on studies of groups exposed to occupational formaldehyde levels.

For oropharyngeal/hypopharyngeal cancers, the human evidence is slight, based on data from highly exposed workers, and slight animal evidence is provided from relevant observations of preneoplastic lesions and mechanistic changes. Taken together, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancers.

The human and animal evidence is indeterminate for laryngeal cancers and, overall, the evidence is inadequate to determine whether formaldehyde inhalation may cause this cancer.

Table 3-43 Evidence integration summary for effects of formaldehyde inhalation on URT cancers

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Nasopharyngeal cancer (NPC)
Human | Consistency and Study Confidence | - Consistent increases in risk across numerous high, medium, and low confidence studies | | Robust Based on large, consistent, and dosedependent increases in risk across numerous high and medium confidence studies in different populations, with strong mechanistic support. | The evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer in humans.; Primarily based on studies of groups of workers exposed to occupational formaldehyde levels, coherent findings in animals (with tumors in rodents generally only at formaldehyde levels above 6 mg/m^3^), and a well-supported MOA for nasal tumor development; Potential Susceptibilities: There is very little evidence to evaluate the potential risk to sensitive populations and/or lifestages. However, several animal studies
Human | Strength and Precision | - Very strong associations (eight studies reported at least a threefold increase in risk for some exposure categories, three of the eight were of high or medium confidence, direction of potential bias toward the null) | | Robust Based on large, consistent, and dosedependent increases in risk across numerous high and medium confidence studies in different populations, with strong mechanistic support.
Human | Dose-Response | - Evidence of exposure-response relationships across multiple measures of increased exposure | | Robust Based on large, consistent, and dosedependent increases in risk across numerous high and medium confidence studies in different populations, with strong mechanistic support.
Human | Coherence | - A temporal relationship consistent with causality (i.e., allowing for cancer induction, latency, and mortality) | | Robust Based on large, consistent, and dosedependent increases in risk across numerous high and medium confidence studies in different populations, with strong mechanistic support.
Human | Biological Plausibility | - Although not as strong as the animal database of mechanistic studies, mechanistic evidence from human studies indicates a clear biological relationship with genotoxicity, epithelial damage and proliferation, and eventual cancer development in relevant URT tissues. | | Robust Based on large, consistent, and dosedependent increases in risk across numerous high and medium confidence studies in different populations, with strong mechanistic support.
Animal | Consistency and Study Confidence | - Tumors of the respiratory tract (predominantly nasal squamous cell carcinomas, SCCs, but including other epithelial and nonepithelial tumors) were consistently observed in mice and in several strains of rats in numerous high and medium confidence studies.; - The development of these lesions, particularly the SCCs, depended on the duration of observation and, based on an increasing incidence and severity of lesions in animals exposed for longer periods of time, the formaldehyde exposure duration.; - Studies of subchronic formaldehyde exposure without follow-up consistently failed to observe dysplasia or neoplasms. Studies with a long observation period were not identified to inform the possibility of cancer development in nonhuman primates exposed to formaldehyde. Given the long development time for these cancers, these findings did not decrease certainty. | - A single medium confidence study in hamsters did not observe tumors. | Robust Based on consistent, dose-dependent, and biologically plausible findings of nasal tumors, primarily SCCs, in mice and rats in numerous high and medium confidence studies, in general after at least 12 months of exposure at formaldehyde levels above 6 mg/m^3^. These lesions were not observed in other regions, such as the larynx and lung. | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Animal | Strength and Precision | N/A | | | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Animal | Dose-Response | - The lesion incidence, as well as the tumor invasiveness and latency, was reproducibly shown to worsen with increasing formaldehyde exposure level.; - The lesions increased in severity and progressed to more posterior locations with increasing duration and concentration of formaldehyde exposure. | | | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Animal | Coherence | - Precancerous dysplastic lesions were induced in rats and mice, sometimes at lower formaldehyde concentrations. | | | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Animal | Biological Plausibility | - Mechanistic changes consistent with cancer development in nasal tissues were observed across species, including rats, mice, and monkeys. In F344 rats chronically exposed to formaldehyde, a clear temporal, doseresponsive, and biological relationship was observed in the appearance of genotoxicity, sustained epithelial damage, cellular proliferation, and eventual tumor development. | | | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Other inferences | - Relevance to humans: The types of findings were consistent and coherent across species (including humans). Although site concordance is not essential (U.S. EPA, 2005a), considering the anatomy of the rodent and human URT and the importance of the distribution of inhaled formaldehyde, the observed formaldehyde exposure-induced nasal tumors and mechanistic changes in animals are considered directly relevant to changes in the human nasopharynx.; - MOA: Together, genotoxicity, cellular proliferation, and cytotoxicity-induced regenerative proliferation exhibit multiple layers of coherence as a function of species, anatomy, temporality, concentration, and duration of exposure, and when integrated, form a biologically relevant MOA for formaldehyde-induced URT carcinogenesis (U.S. EPA, 2005a). While the chronic formaldehyde exposure concentrations reported to elicit nasal cytotoxic pathology appear to be higher in the rats and nonhuman primates evaluated experimentally (≥4 mg/m^3^), compared with the results from human epidemiological cohorts (≥0.3 mg/m^3^), formaldehyde-associated genotoxicity has been induced in analogous POE tissues from rats, nonhuman primates and humans exposed similarly (≤0.9 mg/m^3^). | | | | suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Sinonasal cancer (SNC)
Human | Consistency and Study Confidence | - Consistent increases in risk across a set of four medium confidence studies, with consistent findings in 4 low confidence studies.; - Increased risk of lower magnitude reported by two other medium confidence studies.; - Null results in 3 insensitive low confidence studies did not reduce certainty. | | Robust; Based on large, consistent, and dosedependent increases in risk across four medium confidence studies in different populations, with strong mechanistic support. | The evidence demonstrates that formaldehyde inhalation causes sinonasal cancer in humans; Primarily based on studies of groups of workers exposed to occupational formaldehyde levels. Although less certain than the support provided for NPCs, animal and MOA evidence provide support for the human evidence.; Potential Susceptibilities: There is very little evidence to evaluate the potential risk to sensitive populations and/or lifestages. However, several animal studies suggest that prior damage to the nasal epithelium might increase the development of cancer in these damaged regions.
Human | Strength and Precision | - 2 medium and 2 low confidence studies reported at least a threefold increase in risk, primarily for adenocarcinoma, including the largest study, a pooled analysis of 12 case-control studies | | Robust; Based on large, consistent, and dosedependent increases in risk across four medium confidence studies in different populations, with strong mechanistic support.
Human | Dose-Response | - Four studies above demonstrated a clear exposure-response relationship. | | Robust; Based on large, consistent, and dosedependent increases in risk across four medium confidence studies in different populations, with strong mechanistic support.
Human | Coherence | N/A | | Robust; Based on large, consistent, and dosedependent increases in risk across four medium confidence studies in different populations, with strong mechanistic support.
Human | Biological Plausibility | - The human mechanistic evidence cited for NPC is informative and supportive for interpreting the biological plausibility of SNC (see discussion in MOA analysis). | | Robust; Based on large, consistent, and dosedependent increases in risk across four medium confidence studies in different populations, with strong mechanistic support.
Animal | Consistency and Study Confidence | - (Same evidence base as for NPC; see “Other inferences below, relevance of the animal evidence to human SNC” for justification); [Note: tumors were not reported in the maxillary sinus of exposed animals] | | Robust; [see description for animal evidence supporting NPC above]
Animal | Strength and Precision | | | Robust; [see description for animal evidence supporting NPC above]
Animal | Dose-Response | | | Robust; [see description for animal evidence supporting NPC above]
Animal | Coherence | | | Robust; [see description for animal evidence supporting NPC above]
Animal | Biological Plausibility | - (Same mechanistic evidence base as for NPC); - Although infrequently examined, studies that measured noncancer lesions in the maxillary sinus did not detect treatmentrelated respiratory tract pathology, although cell proliferation was observed (see Section 3.2.4).; - Although also poorly studied, some mechanistic changes consistent with the MOA for nasal cancers, including increased DPX in the monkey maxillary sinus, have been observed. | | Robust; [see description for animal evidence supporting NPC above]
Other inferences | - Relevance of the animal evidence to human SNC: The types of findings were consistent and coherent across species (including humans). The strong animal and mechanistic evidence for nasal cancers across species is interpreted to provide moderate evidence supportive of sinonasal cancer (a judgment of moderate rather than robust reflects some uncertainty in interpreting the nasal cavity findings in animals as fully applicable to human sinonasal cancer specifically; see discussion in MOA analysis).; - MOA: Similar to the inference above, although there is uncertainty in the application of the identified MOA to SNC, the evidence overall is interpreted to provide reasonable support for the mutagenic MOA as applicable to SNC.
Oropharyngeal/ Hypopharyngeal cancer (OHPC)
Human | Consistency and Study Confidence | - Increased risks in two of three medium confidence studies that evaluated multiple metrics of exposure. | - Little evidence of increases in risk (near the null) across one medium and two low confidence results | Slight; Based on coherent and large increases in risk in two studies, with some inconsistent findings in other studies. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Human | Strength and Precision | - Three- to five-fold increases in those highly exposed | | Slight; Based on coherent and large increases in risk in two studies, with some inconsistent findings in other studies. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Human | Dose-Response | - A medium confidence study demonstrated clear exposure-response relationships across several exposure metrics | | Slight; Based on coherent and large increases in risk in two studies, with some inconsistent findings in other studies. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
| Coherence | N/A | | Slight; Based on coherent and large increases in risk in two studies, with some inconsistent findings in other studies. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
| Biological Plausibility | - Although cells from exposed humans in tissues closely apposed to the oropharynx and, more indirectly, the hypopharynx (e.g., buccal cells) demonstrate mechanistic changes consistent with the development of cancer, including genotoxicity, these data were not interpreted as sufficient to further strengthen the human evidence judgment beyond slight. | | Slight; Based on coherent and large increases in risk in two studies, with some inconsistent findings in other studies. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Animal | Consistency and Study Confidence | - Some data suggest that changes in more caudal (e.g., in the trachea) regions, including evidence of dysplasia (a dedicated pre-neoplastic lesion) in one study, can occur with very high formaldehyde exposures and/or different breathing patterns (e.g., oronasal breathing in monkeys). | - The majority of findings in well-conducted animal studies were localized to the nasal cavity. | Slight; Based primarily on supportive mechanistic changes and indirect cancer indicators (the latter only at very high formaldehyde levels) in regions of the respiratory tract most relevant to human OHC. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Animal | Strength and Precision | | - Changes in the more caudal URT tissues most relevant to OHPC were generally less direct indicators of cancer development, were less severe, or occurred only at very high exposure levels. | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Animal | Dose-Response | N/A | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Animal | Coherence | N/A | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Animal | Biological Plausibility | - Mechanistic changes within caudal portions of the rodent and monkey URT have been observed, and oronasal breathing in humans (contrasting nasal-only breathing in rodents) infers an increased potential relevance of mechanistic changes in rostral (anterior) regions of the rodent to human OHPC. However, this was not interpreted as sufficient to further strengthen the evidence judgment beyond slight. | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Other inferences | - Relevance of the animal evidence to human OHPC: While cancer site concordance is not required for hazard determination (U.S. EPA, 2005a), given the known reactivity and distribution of inhaled formaldehyde, a lesser level of confidence in the applicability of the animal nasal findings is inferred for OHPC as compared to NPC or SNC.; - MOA: While aspects of the MOA for nasal cancers, including NPC and SNC, may be operant for OHPC, the evidence overall is not interpreted to provide reasonable support for a MOA that is relevant to OHPC. | | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer^a^
Laryngeal cancer
Human | Consistency and Study Confidence | - Suggestive associations reported in two medium confidence studies; Note: The moderate survival rate for [underlined: laryngeal cancer] may indicate that mortality data are not as good a proxy for incidence. | | Indeterminate; Based on a lack of definitive observations of laryngeal cancer after formaldehyde exposure. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Human | Strength and Precision | N/A | | Indeterminate; Based on a lack of definitive observations of laryngeal cancer after formaldehyde exposure. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Human | Dose-Response | | - Inconsistent evidence on exposure-response relationships | Indeterminate; Based on a lack of definitive observations of laryngeal cancer after formaldehyde exposure. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Human | Coherence | N/A | | Indeterminate; Based on a lack of definitive observations of laryngeal cancer after formaldehyde exposure. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
| Biological Plausibility | Human mechanistic data specifically related to this cancer type are lacking. | | Indeterminate; Based on a lack of definitive observations of laryngeal cancer after formaldehyde exposure. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Animal | Consistency and Study Confidence | | - No studies observed tumors in the rodent or monkey larynx, nor were preneoplastic lesions such as dysplasia detected. | Indeterminate; While some mechanistic changes indicate potential tissue changes in the larynx and related regions in animals, there is an overwhelmingly consistent lack of tumors observed in such areas. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Animal | Strength and Precision | N/A | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Animal | Dose-Response | N/A | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Animal | Coherence | N/A | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Animal | Biological Plausibility | - The evidence for mechanistic changes specifically within the larynx included findings in rodents and monkeys consistent with the MOA for nasal cancers, specifically noncancer lesions (e.g., tissue damage, hyperplasia, and squamous metaplasia) and genotoxicity (i.e., increased DPX). Although these mechanistic changes alone could support a judgment of slight, in the absence of experimental confirmation (or a biological understanding) that these mechanistic changes are likely to lead to cancer or preneoplastic lesions at sublethal formaldehyde concentrations, the animal evidence was judged as indeterminate. | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans
Other inferences | - Relevance of the animal evidence to human laryngeal cancer: The mechanistic changes observed in similar regions of the rodent and monkey URT are considered relevant to the interpretation of laryngeal cancer.; - MOA: No potential MOA was identified for this cancer type. | | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer in humans

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define a quantitative estimate for this cancer type (see Section 5.2).

## 3.3 EVIDENCE FOR NONRESPIRATORY EFFECTS

This section synthesizes research on nervous system effects (see Section 3.3.1), developmental and reproductive toxicity (see Section 3.3.2), and cancer effects beyond the respiratory tract (see Section 3.3.3), specifically in the lymphohematopoietic (LHP) system. Very little information has been reported concerning cancer associations at other nonrespiratory sites (e.g., brain; see Appendix B.3.9 for details). Evidence relevant to assessing carcinogenicity is synthesized for LHP cancer subtypes in Section 3.3.3 (i.e., myeloid leukemia, lymphatic leukemia, multiple myeloma, and Hodgkin lymphoma; note: non-Hodgkin lymphoma was not systematically evaluated: see Appendix B.3.9).

### 3.3.1 Nervous System Effects

Numerous studies suggest that formaldehyde inhalation might result in noncancer nervous system effects; however, the evidence across studies is generally weak and the database is incomplete. Few studies in humans are available, but they reported that formaldehyde exposure was associated with neurobehavioral deficiencies as indicated by poorer performance in tests of short-term memory and psychomotor responses, and with the motor neuron disease, amyotrophic lateral sclerosis (ALS). Observations in rodents include altered performance in tests of locomotion and anxiety, and in learning and memory tests. In many of these animal neurobehavioral studies, a confounding factor was introduced when test animals were exposed to the known neurotoxicant, methanol, in formalin solutions. Experimental animal studies without methanol coexposure suggest that repeated formaldehyde exposure may lead to amplified behavioral responses to certain challenges (e.g., pharmacological), possibly through persistent modifications to neural pathways. Similarly, studies from one laboratory suggest that developmental exposure to formaldehyde at concentrations well above those causing adverse effects on the respiratory system (see Sections 3.2.1−3.2.4) results in long-lasting changes in brain structure. To date, none of these potential nervous system changes are supported by an experimentally verified mechanistic hypothesis outlining how formaldehyde might elicit neurotoxicity without systemic distribution. Overall, a definitive association between formaldehyde inhalation and neurotoxicity could not be concluded. Most of the available experiments had significant study design deficiencies and corroboration across the database was incomplete; thus, overall, the evidence suggests, but is not sufficient to infer, the potential for formaldehyde inhalation to cause nervous system effects in humans (i.e., based on slight evidence from human or animal health effect studies). Additional research is needed to draw a more certain evidence integration judgment.

#### Human Studies

The identified studies describing results of neurobehavioral tests, as well as the occurrence or mortality from neurological disease, are described in this section. These studies are summarized in Tables 3-44 and 3-45. The tables are organized by study design (observational, acute controlled exposure), confidence in study results, and publication year. Three studies were considered not informative (Schenker et al., 1982; Kilburn, 2000; Broder et al., 1988c). The study evaluations are included in Appendix B.3.7.

While several observational epidemiology and controlled exposure studies report nervous system impairment in humans following exposure to formaldehyde, there are notable limitations in the available data and the results from some of the studies are potentially confounded by coexposures. Specifically, data from both observational and experimental studies showed an association between formaldehyde exposure and impaired performance in neurobehavioral tests of memory, dexterity, and psychomotor function (Lang et al., 2008; Kilburn et al., 1987; Kilburn et al., 1989b; Kilburn and Warshaw, 1992; Bach et al., 1990). In prospective studies from one research group, Weisskopf et al. (2009) and Roberts et al. (2015) both noted an association between formaldehyde exposure and death from the fatal motor neuron disease, ALS, in different study populations in the United States; a separate case-control study from another research group in Sweden also identified an association among individuals younger than 65 years of age, but not in the overall analysis using national registry data (Peters et al., 2017). A national registry-based case-control study in Denmark by the same research group in the United States also observed an association (Seals et al., 2017), but a subsequent analysis using the same cases examining joint effects by multiple health and chemical risk factors observed an inverse association in both men and women, although only the latter reached statistical significance (Bellavia et al., 2021). Two other studies failed to identify an association (Pinkerton et al., 2013; Fang et al., 2009). All of the studies were limited by uncertainty in individual exposure assignments, except for the study by Pinkerton et al. (2013), which evaluated a cohort of garment workers with known formaldehyde exposure and detailed information on employment history. The cohort studies were limited by a very low number of exposed cases.

##### Neurobehavioral tests

A series of epidemiology studies examined neurobehavior in histology technicians using standardized test batteries designed to assess higher brain functions (Kilburn et al., 1987; Kilburn et al., 1989b; Kilburn and Warshaw, 1992) (see Table 3−44). It is important to note that the majority of formaldehyde exposure in this occupation is from formalin (containing methanol), which introduced bias due to confounding of unknown magnitude and thus reduced the reliability of the results for interpreting the effects of formaldehyde exposure. All of these studies were ultimately considered to be of low confidence during study evaluation. Decreased performance in multiple tests of memory and tests of dexterity, balance, coordination, motor control, and reaction time was observed with increased daily hours of formaldehyde exposure (Kilburn et al., 1987; Kilburn et al., 1989b). Although these workers were also exposed to solvents that can affect behavior (e.g., xylene), hours of daily exposure to solvents was only correlated with decreased performance in a single memory test (Kilburn et al., 1987; Kilburn et al., 1989b). The effects of formaldehyde exposure on neurobehavior were not verified when a comparable test battery was performed in a slightly larger (350 versus 305 technicians), but possibly overlapping, study (Kilburn and Warshaw, 1992). In addition, a smaller group (n = 19) tested yearly over a 4-year period did not experience worsening effects with continued work exposure, but this analysis did not specifically address formaldehyde exposure (Kilburn and Warshaw, 1992). These latter results suggest a lack of worsening effects with cumulative exposure, but they did not incorporate a consideration of the relative magnitude of exposure (e.g., hours of daily exposure to formaldehyde).

Three acute, controlled exposure studies evaluated performance in standardized neurobehavioral tests (see Table 3−44). Two of these studies included multiple tests assessing concentration, short-term memory, and motor control (Bach et al., 1990; Andersen and Molhave, 1983), while the third focused on decision reaction time (Lang et al., 2008). Although Bach et al. (1990) reported decreased performance in multiple neurobehavioral tests following controlled exposures at ≥0.480 mg/m^3^, particularly in workers with previous chronic formaldehyde exposure, the exposure groups were not well matched for a number of variables relevant to test performance, most of the responses were not concentration dependent, and distractibility due to possible irritation cannot be ruled out (irritation measurements were subjective). In contrast to these results, Andersen and Molhave (1983) indicated that they found no effects of exposure on performance in cognitive tests, but the supporting data were not provided. Increased decision reaction times in response to visual, auditory, or combined visual/auditory stimuli were observed with exposure to 0.369 mg/m^3^ formaldehyde by Lang et al. (2008); the motor component of the reaction times was unaffected by exposure. These increases were not observed at higher exposure levels and did not exhibit the same dose-response pattern as effects on irritation; thus, additional experiments are needed to better explain the findings.

Taken together, the epidemiological and human-controlled exposure studies provide mixed results suggesting that formaldehyde exposure might be associated with deficits in performance in neurobehavioral tests related to learning and memory and motor behavior. However, the reliability of these results is unclear and additional experiments are needed to clarify the potential contributions of variables that are known to affect these measures, but which were poorly controlled in these studies, including coexposures to neurotoxicants, irritation, and differences in population characteristics such as age or education.

Table 3-44 Summary of alterations in neurobehavioral tests in relation to formaldehyde exposure in observational epidemiology and controlled exposure studies

Reference and study design | Exposure measures | Results
Observational epidemiology studies
Reference: Kilburn and Warshaw (1992) (United States); Prospective study; histology technicians attending histology conferences between 1982 and 1987; 19 histology technicians tested yearly across 4 years (46−50 years old); 299 technicians tested 2−3 times across 4 years (44−47.9 years old); 350 histology technicians tested once (38−40.4 years old); sex not reported.; Outcome: 2−3 h neurobehavioral battery; testers blinded to exposure status.; Analysis: Multiple regression, adjusting for age. Other variables considered were sex, years of employment, smoking, and nonoccupational exposures.; Evaluation: ^a^; Low confidence; Potential selection bias, limited detail presented in results. Longitudinal analysis limited by sample size and did not specifically address formaldehyde exposure. | Duration of formaldehyde exposure up to 37 years.; Self-rated exposure scales.; Source of formaldehyde is most likely formalin (containing methanol). | For single test analysis (n = 250), formaldehyde exposure was not associated with age-related change in performance in tests encompassing memory, cognition, pattern recognition, dexterity, decision-making, motor speed, or balance (beta and SE not provided; reported as not statistically significant). No decline seen in smaller group (n = 19) tested across 4 years.
Reference: Kilburn et al. (1987); Kilburn et al. (1989b) (United States) Survey, n = 305 female histology technicians attending histology conference in Boston (167 of 658 in 1982, 25.4% or Anaheim (218 of 704, 31%, in 1983. Age 23–78 years, mean 40 years. Work duration, mean 17 years. Seventynine female referent laboratory technicians in Los Angeles (participation rate not reported).; Outcome: Neurobehavioral battery (10 tests) administered in 1 hour by trained personnel.; Analysis: Multiple regression, formaldehyde (hours) controlling for age, education, smoking, home solvent exposure and number of cover-slipped slides.; Evaluation: ^a^; Low confidence; Potential selection bias (could be influenced by perceived exposure and effects), limited detail presented in results. | Self-reported estimated formaldehyde exposure (average 4.3 hr/d) and xylenes (average 112 cover-slipped slides). Most recent exposures were at least several days prior.; Hour formaldehyde/day correlated with number of slides/day, p < 0.05. Source of formaldehyde is most likely formalin (containing methanol). | Statistically significant association (p < 0.05) between hr/d formaldehyde exposure:; Recall memory (stories): One of two tests; Visual memory (diagram): One of three tests; Associative memory (digit span): One of two tests; Dexterity (pegboard): One of one test Balance (sharpened Romberg): One of one test; Perceptual motor speed (trail making): One of two tests; Age associated with performance decrements in nine tests; solvent exposure (# of slides cover-slipped) associated with one test (p < 0.05); No association with formaldehyde observed for choice reaction time, peripheral nerve function, or spatial relation tests.
Acute, controlled exposure studies
Reference: Lang et al. (2008); (Germany); N = 21 (of 26 volunteers selected based on screening; five left study), 10 women, 11 men (results were combined), age 19–39 years, healthy nonsmokers. Exposure order randomly assigned; double blinded. Ten 4-hour exposures, one per day, over 10 days.; Outcome: Reaction times (Vienna Test System) to visual and acoustic stimuli measured before and after exposures.; Evaluation: Medium confidence Tested immediately after exposure. | Four hours in groups of four.; Formaldehyde levels^a^: Clean air, 0.185, 0.369, and 0.615 mg/m^3^; additional 0.369 and 0.615 mg/m^3^ with peaks up to 1.23 mg/m^3^. Additional 0.0, 0.369, and 0.615 mg/m^3^ with ethyl acetate introduced as a “mask” for formaldehyde. (Analytical concentrations achieved were measured).; Formaldehyde generated from paraformaldehyde, exposure under quasi-static conditions; ethyl acetate at 12–16 ppm (irritant threshold of EA reported at 20 ppm, identified from scientific literature). | ↑ in decision reaction time upon visual stimulus at 0.3 and 0.3+ethyle acetate (data presented graphically, p < 0.05). ↑ in decision reaction time upon acoustic or audio-visual stimulus at 0.3 ppm only (data presented graphically, p < 0.05; comparison group for contrast not stated).; The motor speed component of the decision reaction time was unaffected by exposure.
Reference: Andersen and Molhave (1983); (Denmark); N = 16 healthy students, age 30–33, 68.8% male, 31.2% smokers, groups of four over 4 days.; Exposure order determined by Latin square design, blinding not indicated.; Outcome: Numerical addition: tested 3×/d (once in clean air; twice during exposure); multiplication: tested 1×/d during exposure; card punching tested 2×/d (once in clean air; once during exposure).; Evaluation: Low confidence Tested during exposure; results not reported. | Five hours; 0.3, 0.5, 1.0, and 2.0 mg/m^3^ (analytical concentrations achieved were not reported: indicated as within 20% of target concentrations).; Formaldehyde generation via thermal depolymerization of paraformaldehyde, dynamic chamber. | The study authors reported no change in performance in addition (speed and accuracy), multiplication, or transfer of numbers to punch cards, but data were not provided.
Reference: Bach et al. (1990) (Denmark) 32 with occupational exposure to formaldehyde (>5year); age 18−64 years; selected from 108 workers (recruitment and selection not described). Referent group (n = 29 from 546 selected randomly from a population registry); attempted frequency matching by average age, education, and smoking prevalence but workers had higher smoking prevalence and lower education (detailed demographic data not reported). Formaldehyde-exposed excluded from referent group.; Exposure order by balanced Latin square design; double blinded—Furfuryl mercaptan (coffee aroma) used to mask odor.; Outcome: Four performance tests twice during exposure.; Evaluation: Low confidence; Education and smoking imbalance in workers and referents; tested during acute exposure. | 5.5 hr (0.5 hr pre-exposure in chamber and gradual increase in formaldehyde).; Formaldehyde vapor generation not reported; however, assumed to be from depolymerization of paraformaldehyde based on protocols used in the same exposure chamber as reported by a coauthor (Andersen and Molhave, 1983).; Formaldehyde concentrations 0, 0.15, 0.4, and 1.2 mg/m^3^ [analytical concentrations achieved: 0.04, 0.21, 0.48, and 1.10 mg/m^3^]. | Occupational group showed significantly ↓ performance on the digit symbol test (p < 0.025 for pooled exposure groups, 0, 0.15, and 0.4 compared to 1.2 mg/m^3^); controls showed an inverse relationship; digit span (p < 0.025) for total digit sum in one of the six test components—lowest scores in 0.4 mg/m^3^ group, and graphic continuous line test (p < 0.05 only for the 0.4 mg/m^3^ group); effects were not dose-related. Addition test: Dose-related performance decrements (↓ # of additions and ↑ reaction time).; Data were presented graphically.; Matching was not completely successful; due to last-minute substitutions, the exposed workers, particularly the 1.2 mg/m^3^ group, had a lower education and different proportion of smokers; the 1.2 mg/m^3^ group had a lower average age and fewer smokers overall. Exposure groups were not comparable.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.7). Results from low confidence studies are shaded; these findings are considered less reliable.

b Formaldehyde levels in the study converted to mg/m^3^ from ppm (1 ppm = 1.23 mg/m^3^).

##### Nervous system disease

In a large and well-designed, prospective study of risk factors associated with amyotrophic lateral sclerosis (ALS) mortality, years of self-reported exposure to formaldehyde was associated with a 2.5−fold (95% CI 1.58, 3.86) increased mortality risk when examined across individuals reporting duration data (this information was available for 22 of the 36 cases reporting formaldehyde exposure) (Weisskopf et al., 2009) (see Table 3−45). The overall risk was no longer significantly elevated when individuals who reported exposure but did not report duration were included in the analysis (all 36 cases; RR = 1.34; 95% CI 0.93,1.92). Risk increased with increasing duration of formaldehyde exposure, with a fourfold risk seen with >10 years of exposure (13 cases). In total, Weisskopf et al. (2009) followed 987,229 people and identified 1,156 ALS deaths (1,120 of these cases reported that they were not exposed to formaldehyde), but formaldehyde intensity was not assessed, and the duration of exposure was self-reported. A second study from the same research group also identified some evidence of an association between formaldehyde exposure and ALS death in a national study (Roberts et al., 2015). An odds ratio (OR) of 4.43 was observed among individuals with a high probability, high intensity exposure, based on only two cases of ALS; no cases were observed among individuals with high probability, medium intensity exposure. Formaldehyde exposure assignments were made by industrial hygienists using a job-exposure matrix with estimates of intensity and probability of exposure for the most recent job held by participants, although duration was not assessed. More recently, two registry-based studies in Sweden and Denmark observed associations of similar magnitude between ALS diagnosis and occupational formaldehyde exposure analyzing all incident ALS cases occurring over a 20- to almost 30-year period. Both studies used a job-exposure matrix (JEM) developed for the Nordic Occupational Cancer Study (NOCCA) with exposure data specific to each country. The Swedish study observed no association in the entire analytic group of blue-collar workers and farmers, however an odds ratio of 1.28 (95% CI 1.02, 1.61) was observed when the analysis was restricted to persons younger than 65 years of age (Peters et al., 2017). In Denmark, occupational exposure to formaldehyde was associated with ALS incidence in the entire cohort using a nonspecific exposure definition (ever/never) (RR 1.3, 95% CI 1.2, 1.4) and associations of the same magnitude were observed across all exposure quartiles in comparison to nonexposed (Seals et al., 2017). Hence neither study observed an (exposure-response trend. Also, the potential effect of confounding by smoking on the formaldehyde—ALS association (Wang et al., 2011; Armon, 2009) was not addressed. Paradoxically, the direction of the association was reversed when investigators used a machine learning method to select joint predictors and interaction terms and then included these health and chemical risk factors for ALS in the model (Bellavia et al., 2021). An OR of similar magnitude but less precise than that reported by Peters et al. (2017) (OR = 1.3; 95% CI 0.5, 3.2) was observed for participants with a high probability of exposure in a small case-control study, although no association with exposure duration was observed (Fang et al., 2009). Although the longitudinal design of the prospective studies makes it unlikely that the association between formaldehyde exposure and ALS death is attributable to some types of bias, a study with detailed evaluations of formaldehyde exposure (probability, frequency) and duration of exposure in the exposed populations failed to confirm an association (Pinkerton et al., 2013). Exposure in the cohort of garment workers (Pinkerton et al., 2013), in particular, was more certain, based on monitoring data in the 1980s, year of hire, and years of employment. However, all of the studies, except Peters et al. (2017) and Seals et al. (2017) were limited by small numbers of exposed cases, which leads to decreased sensitivity to detect an association that might exist, or decreased stability in effect estimates (see Figure 3-27). Overall, evidence is emerging that formaldehyde exposure may pose a hazard for ALS, but there is a large degree of uncertainty due to the mixed nature of the findings. As risk factors for increased risk of ALS are complex and poorly defined, it remains possible that the findings of Weisskopf et al. (2009), and the less robust but supportive findings by Roberts et al. (2015), Peters et al. (2017) and Seals et al. (2017), identify a true risk of formaldehyde exposure. However, additional research designed to address the identified limitations would help to clarify these study results.

Figure 3-27 Human studies of medium confidence examining the potential for formaldehyde exposure to cause ALS

Seven epidemiological studies of medium confidence were identified, all of which examined potential associations with amyotrophic lateral sclerosis (ALS) [notes: a medium confidence, acute controlled exposure study of neurobehavior, Lang et al. (2008), is not presented; results from Roberts et al. (2015) are only presented for males as all results in females were null]. Estimates of risk (i.e., odds ratios [ORs], standardized mortality ratios [SMRs], relative risks [RRs], or hazard ratios [HRs]), 95% confidence intervals (CIs), and number of exposed cases or deaths are presented for different comparisons within the studies, including full cohort (e.g., ever/never exposed) comparisons (unlabeled) and comparisons across multiple groups by: increasing duration, probability (prob.), time since first exposure (TFSE) [note: null results comparing date of first exposure in Pinkerton et al. (2013) are not shown], or age-restricted (e.g., younger than 65 years: ≤65). Different shapes reflect different research groups. Other abbreviations: F_D_ = full cohort comparison excluding persons not providing duration information; I_P_ = maximum intensity in persons with a high probability of exposure compared to controls; M = males; F = females; all = overall (full cohort comparisons).

Table 3-45 Summary of human studies of nervous system disease risk in relation to formaldehyde exposure

Reference and study design | Exposure measures | Results
Observational epidemiology studies
Reference: Pinkerton et al. (2013) (United States) Prospective cohort, 11,098 garment workers (82% women) exposed to formaldehyde-treated fabric for ≥3 mo. (late 1950s to early 1980s).; Outcome: Vital status through 2008, underlying cause of death, ICD-10 G12.2, ICD-9 335.2, ICD-8 348.0 and ICD-7 356.1.; Analysis: Life-table analysis based on U.S. population, excluded missing birth date (n = 55), deaths (n = 8), lost to follow-up prior to date file begin date (n = 13); SMRs and 95% CI, adjusted for age, calendar time, sex, race; no information on smoking.; Evaluation: ^a^; Medium confidence; Small number of cases. | Monitoring in 1980s, geometric mean 0.15 ppm (GSD 1.9 ppm), constant levels across departments and facilities, year of first exposure (42% before 1963), time since first exposure (median 39.4 years) and exposure duration (median 3.3 years); no other exposures associated with ALS. | Amyotrophic lateral sclerosis mortality; N = 11,022, 414,313 person-years at risk; eight ALS deaths; mortality for COPD and lung cancer in cohort was similar or greater than national rates (Meyers et al., 2013) indicating that possible confounding by smoking would be in direction away from the null, not a concern for these null results.; All eight deaths were recorded due to ALS in death certificates.
| | | | Deaths | SMR (95% CI)
| | Overall | | 8 | 0.89 (0.38, 1.75)
| | Year of 1^st^ exposure
| | Before 1963 | | 5 | 0.84 (0.27, 1.96)
| | 1963–70 | | 3 | 1.29 (0.27, 3.78)
| | ≥1973 | | 0 | 0.00 (0.00, 4.92)
| | Duration
| | <3 year | | 2 | 0.61 (0.07, 2.21)
| | 3–9 year | | 3 | 1.17 (0.24, 3.41)
| | 10+ year | | 3 | 0.94 (0.19, 2.75)
| | TSFE^a^
| | <10 year | | 1 | 3.50 (0.09, 19.52)
| | 10–19 year | | 0 | 0.00 (0.00, 4.19)
| | 20+ year | | 7 | 0.89 (0.36, 1.83)
| | ^a^TSFE: time since first exposure
Reference: Bellavia et al. (2021) (Denmark) Population-based case-control ALS cases, 1982-2009, from Seals et al. (2017) with complete data for several health factors and environmental risk factors previously linked with ALS (N = 1086). Controls, 100 per case matched on being alive on index date for case diagnosis, same birth year and sex (N = 111,507). Excluded individuals with less than 5 years work experience.; Outcome: see Seals et al. (2017); Analysis: Selected joint predictors and interactions using boosted regression trees and Logic regression, which were included in a logistic regression model adjusting for age, SES, and geography. Model used a 3-year lag. Evaluated diabetes, obesity, physical/ stress trauma, CVD (1977-2009) and lead, diesel exhaust and solvents.; Evaluation: ^a^; Low confidence; Large uncertainty regarding exposure assessment (ever/never exposed). Adequacy of 3-year lag is unknown. | see Seals et al. (2017) Formaldehyde exposure metric was ever/never exposed. Anticipate exposure misclassification and large variation in prevalence and intensity of exposure across individuals. In men, correlations between formaldehyde, diesel exhaust and solvents were 0.22 and 0.41, respectively (Phi coefficients) | Amyotrophic lateral sclerosis
| | Ever formaldehyde Exposed
| | Controls N (%) | | Cases N (%) | OR (95% CI)
| | Men | 43,760 (0.64) | 422 (0.63) | 0.87 (0.73, 1.04)
| | Women | 28.100 (0.65) | 255 (0.61) | 0.86 (0.84,0.89)
| | Logistic regression mutually adjusting for age, SES, and geography, diesel exhaust (male), solvents, trauma, CVD, diesel*CVD (male), solvents*trauma (male), diesel*trauma (male), and diesel*solvents (male), lead (female), lead*solvents (female) and trauma*formaldehyde (female).
Reference: Seals et al. (2017) (Denmark) Population-based case-control study, Registry-based case identification using the Danish National Patient Register, 1982-2009 (3650 incident cases). Controls obtained from Central Person Registry (All Denmark residents since 1968), 4 per case matched on sex, age, and no ALS diagnosis in Hospital Register as of date of diagnosis for matched case (index date).; Outcome: Cases identified from Danish National Patient Register, discharge diagnosis ICD-8 348.0 or ICD-10 G12.2. Case definition was 1^st^ diagnoses on or after 1/1/1982–12/31/2009.; Analysis: Conditional logistic regression adjusted for age, sex, index date, SES, marital status and residence. No information on smoking status.; Evaluation: ^a^; Medium confidence; Uncertainty regarding exposure assessment. JEM not validated to predict formaldehyde exposure level. | Occupational histories obtained from Danish Pension Fund databases. Used NOCCA (Nordic Occupational Cancer Study)- Danish JEM for periods 1960-74, 1975-84, and 1985 and after. Inputs year and industry code and outputs prevalence of exposure for each job along with expected exposure level (ppm) in exposed. The JEM has not been validated to estimate levels. Cumulative expected exposure calculated (prevalence multiplied by expected level) summed over jobs and time (3- and 5-year lags). Exposure misclassification expected due to variation of tasks within industries. | Amyotrophic lateral sclerosis
| | Exposure | Controls N (%) | Cases N (%) | RR (95% CI)
| | None | 10,934 (75) | 2582 (71) | 1.0 (ref)
| | Ever | 3666 (25) | 1068 (29) | 1.3 (1.2, 1.4)
| | Quartiles (mg/m^3^)
| | <0.016 | 935 (6.4) | 262 (7.2) | 1.3 (1.1, 1.5)
| | 0.016-0.1 | 976 (6.7) | 272 (7.5) | 1.2 (1.1, 1.4)
| | 0.1-0.34 | 873 (6.0) | 268 (7.3) | 1.4 (1.2, 1.6)
| | >0.34 | 882 (6.0) | 266 (7.3) | 1.3 (1.1, 1.5)
Reference: Peters et al. (2017) (Sweden) Nested case-control study, 5,020 patients diagnosed with ALS between 1991 and 2010 and 25,100 Swedish controls (5 per ALS case) matched by birth year and sex, alive on case’s date of diagnosis; source population born 1901−1970 and included in the 1990 Swedish Population and Household Census (includes persons living in Sweden for ≥1 year).; Outcome: Cases identified from National Patient Register (primary or secondary diagnosis) through 2010 (ICD-9 335C; ICD-10 G12.2).; Analysis: Conditional logistic regression with adjustment for education and other 11 exposures examined; restricted to individuals with at least one occupation registered in any of the censuses, occupations listed in censuses 10 years before diagnosis, and either blue collar workers or farmers (2,647 cases, 13,378 controls).; Evaluation: ^a^; Medium confidence; Uncertainty regarding exposure assessment. | Individual occupational histories obtained from 1970, 1980, and 1990 censuses; Swedish version of Nordic Occupational Cancer Study JEM (industrial hygienist estimates of prevalence and level of specific exposures at specific calendar times). Dose-response: exposure metric calculated: prevalence multiplied by annual mean level of exposure in a specific occupation at the time of a census, averaged over all three censuses, dichotomized at mean level in controls. | Amyotrophic lateral sclerosis
| | | Cases | Control | OR (95% Ci)
| | Restricted analytic sample (2,647 cases)
| | All | 323 | 1,579 | 1.07 (0.92-1.25)
| | Exposure metric (mg/m^3^)
| | Not exposed | 659 | 3,341 | 1.0 (Reference)
| | ≤0.013 | 30 | 185 | 0.89 (0.58–1.36)
| | ≥0.013 | 53 | 210 | 1.31 (0.86–1.99)
| | Restricted to individuals <65 years old at diagnosis (1,014 cases)
| | All | 140 | 576 | 1.28 (1.02–1.61)
Reference: Roberts et al. (2015) (United States) Prospective cohort, 1,469,235 occupational workers (46% women); National Longitudinal Mortality Study (NLMS) restricted to age 25+ at initial survey. Participants provided follow-up from survey until 2011 or death.; Outcome: NLMS records matched to the National Death Index (1979–2011) with underlying cause of death as ALS: ICD-10 G12.2 or ICD-9 335.2.; Analysis: HRs estimated for each exposure level using survival analyses with age as the time variable, separate models for men and women, adjusted for education, race/ethnicity, and income.; Evaluation: ^a^; Medium confidence; Uncertainty regarding exposure assessment, including the influence of duration, no information about job history prior to most recent job; very small number of exposed cases (n = 2 in jobs with high probability and intensity of formaldehyde exposure).; Note: same laboratory, data handling, and analysis methods as Weisskopf et al. (2009). | Exposure matrix by industrial hygienists at the National Cancer Institute (see (Wang et al., 2009)) was constructed based on participant survey at enrollment regarding their last or most recent job; no information or adjustments for other potential exposures. | Amytrophic lateral sclerosis mortality; N = 757 total ALS deaths (472 deaths in men, with 100 exposed cases and 12,930,240 total person-years in men).; Duration not evaluated.; No information on mortality from smoking-related disease or smoking in the general cohort. Deaths matched to ALS in death certificates. No increased risk of ALS in women (data not shown): authors attribute this to occupation role.; ALS deaths in men
| | | | Deaths | HR (95% CI)
| | [underlined: Intensity]
| | Unexposed | | 372 | 1.0 (Reference)
| | Low | | 55 | 0.99 (0.74, 1.30)
| | Medium | | 43 | 0.63 (0.44, 0.90)
| | High | | 2 | 1.53 (0.4, 5.80)
| | [underlined: Intensity, restricted to probability = high]
| | Unexposed | | 372 | 1.0 (Referent)
| | Low | | 0 | -
| | Medium | | 0 | -
| | High | | 2 | 4.43 (1.16, 16.85)
| | [underlined: Probability]
| | Unexposed | | 372 | 1.0 (Reference)
| | Low | | 51 | 0.85 (0.63, 1.15)
| | Medium | | 47 | 0.76 (0.54, 1.06)
| | High | | 2 | 2.98 (0.78, 11.30)
| | Probability, follow-up to age 75 only
| | Unexposed | | 332 | 1.0 (Reference)
| | Low | | 41 | 0.79 (0.57, 1.11)
| | Medium | | 40 | 0.66 (0.44, 0.99)
| | High | | 2 | 4.13 (1.09, 15.69)
| | Probability, aged 50–75 at enrollment
| | Unexposed | | 197 | 1.0 (Reference)
| | Low | | 31 | 1.00 (0.67, 1.49)
| | Medium | | 27 | 0.75 (0.47, 1.19)
| | High | | 2 | 4.76 (1.16, 19.49)
| | Probability analyses excluding the first 5 years of follow-up or restricted to men aged 35–75 at enrollment, or to those employed at enrollment, are not shown (results were similar to the overall probability analysis).
Reference: Fang et al. (2009) (United States) Case-control study, 111 cases and 256 controls; sequential ALS cases recruited, 1993−1996, from two major referral centers; cases and controls lived in New England at least 50% of year, mentally competent, English speakers; 71% of eligible cases participated; controls by random telephone screening, frequency matched on sex, age (three groups), and region, 76% of eligible (256 of 270 completed questionnaires).; Outcome: Diagnoses by board-certified specialists in motor neuron disease using World Federation of Neurology El Escorial criteria (Brooks, 1994).; Analysis: Unconditional logistic regression models; tested linear trend with lifetime exposure days, probability, and weighted exposure duration (four categories); adjusted for age, sex, area of residence, smoking (ever/never), and education.; Evaluation: ^a^; Medium confidence; Uncertainty regarding exposure assessment; small number of exposed cases. | Occupational history by structured questionnaire; industry, occupation, frequency, and duration; jobs held before ALS diagnosis or 2 years before interview (controls); formaldehyde-exposed occupations identified a priori by industrial hygienist; calculated life-time hours of exposure to formaldehyde weighted by probability of exposure in specific jobs. | Amytrophic lateral sclerosis; Association of ALS risk with occupational formaldehyde exposure (109 cases, 253 controls)
| | | Controls | Cases | OR (95% CI)
| | Never^a^ | 204 | 89 | Ref.
| | Ever | 49 | 20 | 0.8 (0.5, 1.5)
| | Exposure Probability^b^
| | 0−1 | 7 | 2 | 0.6 (0.1, 2.8)
| | 1 | 27 | 9 | 0.7 (0.3, 1.6)
| | 2 | 15 | 9 | 1.3 (0.5, 3.2)
| | Trend p-value | | | 0.50
| | Weighted exposure duration (hr)^c^
| | ≤10,000 | 14 | 7 | 1.1 (0.4, 2.8)
| | 10,001–40,000 | 19 | 8 | 0.8 (0.3, 1.9)
| | >40,000 | 16 | 5 | 0.7 (0.2, 2.0)
| | Trend p-value | | | 0.45
| | >60,000^d^ | 4 | 4 | 3.0 (0.7, 12.9)
| | ^a^Referent was group with no previous. occupational exposure to formaldehyde; ^b^Highest probability ever experienced.; ^c^Weights were 0.5, 1, and 2 for probabilities 0−1, 1, and 2.; ^d^Additional analysis.
Reference: Weisskopf et al. (2009) (United States) Prospective cohort, 987,229 men and women. American Cancer Society Cancer Prevention Study II. No major illness at baseline in 1982. Follow-up from 1989 through 2004.; Outcome: Cause of death obtained for >98% of known deaths; underlying or contributing cause. ICD-9 (1989−1998) code 335.3; ICD-10 (1999−2004) code G12.2 (ALS represents >98% of these categories).; Analysis: Cox proportional hazards modeling, adjusted for age, sex, smoking, military service, education, alcohol, occupation (farmer, lab technician, machine assembler, programmer), vitamin E use, and the other chemical (and Xrays) exposures assessed at baseline.; Evaluation:^a^; Medium confidence; Uncertainty regarding exposure assessment. | Self-report (at baseline, 1982) of current or past regular exposure to formaldehyde (and duration); data on 10 other types of chemicals and X-ray exposure also collected.; Source(s) of formaldehyde exposure were not defined; likely to be occupational settings. | Amyotrophic lateral sclerosis mortality; 1,156 ALS deaths; mortality rate 11.3 and 6.7 per 100,000 person-years in men and women, respectively.
| | | N cases exposed | RR | (95% CI)
| | Full cohort | 36 | 1.34 | (0.93, 1.92)
| | With
| | duration^a^ | 22 | 2.47 | (1.58, 3.86)
| | <4 years | 4 | 1.5 | (0.7, 4.2)
| | 4−10 | 5 | 2.1 | (0.9, 5.4)
| | >10 | 13 | 4.1 | (2.2, 7)
| | CIs estimated from graph; RR between other exposures and ALS ranged from 0.68 to 1.44.; ^a^“With duration” indicates the subset of the full cohort after excluding individuals not providing duration information.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.7).

Abbreviations: ALS = amyotrophic lateral sclerosis; COPD = chronic obstructive pulmonary disease; GSD = geometric standard deviation; CI = confidence interval; SMR = standardized mortality ratio.

##### Summary of Human Evidence Synthesis Judgments

###### Neurobehavioral Tests

The following factors were influential to the synthesis judgment that the human studies provide slight evidence of formaldehyde exposure-induced neurobehavioral effects, specifically on motor behaviors and learning and memory. No human studies informed potential neural sensitization.

###### Motor behaviors

- Consistency and Study Confidence: Two low confidence studies, with weak support from one medium confidence study, observed effects on motor-related behaviors. All low confidence studies had significant coexposures and/or poorly comparable groups, reducing certainty.
- Dose-Response: Certainty is decreased due to a lack of dose-dependence.

###### Learning and Memory

- Consistency and Study Confidence: Three of four low confidence studies observed effects in tests of learning or memory. All studies had significant coexposures and/or poorly comparable groups, reducing certainty.
- Dose-Response: Certainty is decreased due to a lack of dose-dependence, although exposure duration was associated with decrements in learning and memory.

###### Nervous System Disease

The following factors, particularly the generally consistent findings across a few studies, were influential to the synthesis judgment that the human studies on nervous system disease provide slight evidence of a formaldehyde exposure-induced increase in amyotrophic lateral sclerosis (ALS) incidence and mortality.

- Consistency and Study Confidence: Clear effects were observed in one medium confidence study with more limited support from three other medium confidence studies, two of which were from the same research group. Conversely, no association was observed in a medium confidence study using a longitudinal design and more robust exposure assessment. Overall uncertainty exists due to small numbers of exposed cases.
- Strength and Precision: One medium confidence study observed large, precise increases.
- Dose-Response: Certainty is decreased by a lack of dose-response trends in the studies able to examine it, and because exposure duration was inconsistently associated with disease incidence.
- Biological Plausibility: Certainty is decreased because plausibility is lacking for how inhaled formaldehyde, which is not appreciably distributed to the central nervous system, could impact ALS. No MOA or informative mechanistic studies were identified.
  In addition to the judgment above, it is noted that ALS disproportionately affects males.

###### Developmental Neurotoxicity

No informative human studies related to developmental neurotoxicity were identified (i.e., indeterminate human evidence).

#### Animal Studies

Numerous experimental animal studies report findings of neurobehavioral and structural alterations following formaldehyde inhalation. This section discusses these studies according to the type of evaluation(s) performed, specifically by studies of neuropathology (see Table 3-46), studies examining potential sensitization of the nervous system (see Table 3-47), tests of general motor-related behaviors (see Table 3-48; as discussed below, most of the available studies used tests that evaluated responses that may be related to motor function and other behaviors, such as responses to increased anxiety), and tests of learning and memory (see Table 3-49). The evidence tables are organized by study confidence and descending publication year. The study evaluations are included in Appendix B.3.7.

As discussed below, much of the available data are difficult to interpret due to potential coexposures (e.g., methanol), possible mischaracterization of irritation-related behaviors as central nervous system- (CNS)-mediated effects, unreported or inadequate study design methods, and unclear dose-response relationships. The neurobehavioral effects reported following formaldehyde inhalation include changes in motor function, anxiety, habituation, learning and memory, and chemical sensitization in adult animals (Usanmaz et al., 2002; Sorg et al., 1998; Sorg and Hochstatter, 1999; Sorg et al., 2001b; Sorg et al., 2004; Pitten et al., 2000; Malek et al., 2003a, b, c, 2004; LICM, 2008; Boja et al., 1985). Nociception was unaffected in one study (Sorg et al., 1998). Several studies also indicate neuropathology or behavioral effects following developmental formaldehyde exposure (Songur et al., 2003; Sheveleva, 1971; Sarsilmaz et al., 2007; Aslan et al., 2006); no corresponding information on developmental nervous system effects in human studies is available.

In addition to these studies evaluating specific effects on the nervous system, one subchronic study (Woutersen et al., 1987) and three chronic studies (Tobe et al., 1985; Kerns et al., 1983; Appelman et al., 1988) designed to assess the general toxicity or carcinogenicity of formaldehyde reported general behavioral effects (e.g., uncoordinated locomotion) following exposure to high levels of formaldehyde (>12 mg/m^3^). In these studies, no overt changes in absolute brain weight, brain histopathology, or performance in simple tests of nervous system function were observed (data not shown). These general toxicity and carcinogenicity studies were not specifically designed to assess nervous system function and did not report many of the relevant procedural details or, in most cases, the specific quantitative results. Thus, a confidence rating was not assigned to these experiments, and they are not discussed further. Studies on odorant detection (not considered a potential adverse effect of formaldehyde) were also reviewed (see Appendix B.3.7) and are briefly discussed to inform the interpretation of specific nervous system effects (e.g., behavioral changes). Aside from these cursory examinations and one subchronic experiment with brief, 10-minute, daily formaldehyde exposures (Pitten et al., 2000), the remaining animal studies of the potential for nervous system effects due to formaldehyde inhalation relied on exposures of acute or short-term duration; extrapolation of these effects to long-term exposure scenarios is difficult. Studies classified as not informative to the animal or MOA evidence syntheses are not discussed (Yu and Blessing, 1997, 1999; Wang et al., 2014a; Tepper et al., 1995; Tani et al., 1986; Sorg et al., 1996; Sorg et al., 2002; Senichenkova, 1991a; Sari et al., 2005; Nalivaiko et al., 2003; Morgan et al., 1986a; Mei et al., 2016; Maronpot et al., 1986; Liu et al., 2009; Liu et al., 2010; Liao et al., 2010; Katsnelson et al., 2013; Gieroba et al., 1994; DHGC, 2010; Coon et al., 1970; Chonglei et al., 2012; Bokina et al., 1976; Bian et al., 2012; Apfelbach and Weiler, 1991), noting that some studies deemed not informative for certain endpoints were informative for other endpoints and are discussed below (see Appendix B.3.7 for details). Figure 3−28 presents all of the medium or low confidence experimental animal studies identified (no high confidence studies were identified), whereas the data from the medium confidence animal studies are summarized in greater detail in Figure 3−29.

Figure 3-28 Nervous system effects in animal studies

As no high confidence experimental animal studies were identified, the available studies are organized by medium and low confidence study evaluation interpretations (see Appendix B.3.7), then by endpoint, then by timing of exposure (i.e., developmental [devel.] or adult). Filled symbols indicate statistically significant effects, and the size of the points reflecting the sample size for that formaldehyde exposure group (larger size = larger n). The low confidence experiments are shown on a gray background, as the identified study limitations substantially reduce confidence in the reliability of the results; these low confidence experiments contribute very little to the weight of evidence for nervous system effects. Note: “Activity” refers to motor-related behaviors (e.g., open field activity). *The studies by Aslan et al. (2006) and Sarsilmaz et al. (2007) report data from the same cohort of exposed rats.

Figure 3-29 Medium confidence animal studies of nervous system effects

The evidence for nervous system effects reported in medium or high confidence experimental animal studies is arrayed (note: no high confidence studies were identified). Two studies examined developmental neuropathology using stereological methods after postnatal exposure to 7.4−14.8 mg/m^3^ formaldehyde in a single cohort of rats (Sarsilmaz et al., 2007; Aslan et al., 2006), while a third study evaluated sensitization-type responses in adult rats at 1.23 mg/m^3^ (Sorg et al., 1998). ^1^Results are displayed as fold change from control animals (control responses at 1 are illustrated as a dashed line), with variability in both the controls and treatment groups represented by the quotient (ratio) of the 95% CI, as calculated based on the method described by E.C. Fieller (Cox and Ruhl, 1966), which assumes Gaussian distributions. ^a^Changes in vertical activity induced by stimulation with cocaine exposure following formaldehyde inhalation for 7 or 20 days and several days (“early”) or several weeks (“late”) of nonexposure are shown; the authors did not observe any changes in cocaine-induced horizontal activity (not shown). *p < 0.05, as reported by study authors. Note: all results were estimated from data presented graphically using Grab It!™, Datatrend Software.

##### Neuropathology, including Developmental Neurotoxicity

Several studies examined the effects of formaldehyde inhalation on brain neuropathology. Evidence of changes in brain structure and neuron number following developmental exposure to ≥7.38 mg/m^3^ formaldehyde has been described in three publications from one laboratory (Songur et al., 2003; Sarsilmaz et al., 2007; Aslan et al., 2006) (see Table 3−46). Two of these studies (Sarsilmaz et al., 2007; Aslan et al., 2006) were evaluations of the same cohort of animals. No overt changes in CNS pathology have been reported following subchronic or chronic formaldehyde exposures in adult rats at concentrations ranging from 0.369 to 18.5 mg/m^3^ (Tobe et al., 1985; Pitten et al., 2000; Kerns et al., 1983; Appelman et al., 1988), although the methods employed in the adult animal studies were far less sensitive than those used by Sarsilmaz et al. (2007) and Aslan et al. (2006).

Neuropathological alterations were evident in male rats following exposure to 7.38 or 14.8 mg/m^3^ formaldehyde from postnatal day (PND) 1 to PND 30. Specifically, in the cornu ammonis (CA) region of the hippocampus, a 4% (at 7.38 mg/m^3^) or 22% (at 14.8 mg/m^3^; statistically significant) decrease in the number of neurons in the pyramidal cell layer was observed at PND 30, and statistically significant, 8−9%, decreases were still observable at both concentrations at PND 90 (Sarsilmaz et al., 2007). Although the morphology of the cell nuclei determined by cresyl violet staining was indicated as normal in all regions of the hippocampus at PNDs 30 and 90 in Sarsilmaz et al. (2007) and Aslan et al. (2006), these decreased cell counts were consistent with separate observations of robust increases (59−322%) in the number of pyknotic (i.e., dying) CA neurons at PNDs 30 and 60 in Songur et al. (2003). A decrease in cell number is considered an adverse effect and a specific indicator of toxicity. The decreased magnitude of neuronal loss at PND 90 as compared to PND 30 (Sarsilmaz et al., 2007), along with a separate observation that pyknotic CA neuron counts were no longer elevated at PND90 (Songur et al., 2003), suggest some measure of recovery or adaptation 60 days after exposures were terminated. Notably, hippocampal cell number exhibits a natural decrease between PNDs 30 and 90, as demonstrated by Sarsilmaz et al. (2007) and Aslan et al. (2006).

Changes in the hippocampal dentate gyrus (DG) cell number and in volumetric measures were less clear. A significant increase in DG volume was observed at ≥7.36 mg/m^3^ formaldehyde at PND 30, without any accompanying changes in cell number (Aslan et al., 2006). The authors attributed this finding to possible formaldehyde-triggered inflammation during postnatal growth of the DG, which continues until ~PND 28; however, this hypothesis was not evaluated by immunostaining. At PND 90, although DG cell number was decreased at 14.8 mg/m^3^, DG volume and cell number were elevated at 7.36 mg/m^3^. In contrast to decreases in cell number, an increase in cell number is not necessarily adverse. Although CA cell counts were decreased, the volume of the pyramidal cell layer on PND 30 was increased at 7.38 mg/m^3^ but decreased at 14.8 mg/m^3^; neither exposure group was significantly different from controls on PND 90. Changes in brain hemisphere volume [decreased at PND 30 and increased at PND 90; (Sarsilmaz et al., 2007)] suggest formaldehyde-induced structural changes or inflammation in nonhippocampal regions, or altered ventricular parameters, as the changes were not consistent with volume changes in the DG or CA regions. Volume changes can provide nonspecific measures of neural health. Although these changes are sometimes associated with regional atrophy and degeneration, they are also sensitive to variations such as changes in neuron size or changes in the size or number of nonneuronal cells. Thus, decreased cell number is a more specific indicator of toxicity.

Exposure from PND 1 to PND 30 covers a sensitive window of hippocampal development, as a large percentage of hippocampal neurons, particularly in the DG, are generated or mature (e.g., establish permanent connections) during the early postnatal period. In addition, the stereological methods used by Aslan et al. (2006) and Sarsilmaz et al. (2007) are extremely sensitive and unbiased by design (e.g., sampling is random and systematic). These methods were not applied in any other studies, highlighting a key uncertainty in the database. The specific exposure window or methods employed could explain the general lack of overt neuropathological effects in rats exposed as adults. Importantly, these developmental studies did not appear to evaluate possible effects on nursing dams (i.e., dam health and behavior), who appear to have been exposed along with the pups from PND 1 to PND 14. It is plausible that the high-level exposures could lead to nutritional changes that influence measures of structural brain development. Pup health, which was affected at PND 30 (i.e., decreased body weight) but not PND 90 in the study by Songur et al. (2003), was not reported in the other two studies. However, CA neuron loss was still evident at PND 90 when no body-weight differences were evident (Songur et al., 2003). An additional significant limitation of these studies is that the sample size is very small considering that the analyses were performed on a pup basis rather than a litter basis, as would be preferred. Specifically, although 5−6 pups/group were analyzed, because litter effects may influence these measures, the data are better evaluated as representing only N = 3 litters (the authors indicate two pups were assessed from each of the three litters). Litter data were not available to determine whether such analyses would result in a greater or lesser magnitude of response, further complicating interpretation.

Complete recovery of the observed neuropathology following developmental exposure was not observed. Partial recovery was apparent, but examinations did not continue long enough to detect whether or when the observed pathology completely resolves. This supports the possibility that formaldehyde may cause long-lasting or permanent neuroanatomical changes in the brain following early-life exposure, which would substantiate characterizing it as a nervous system hazard according to Agency guidelines (U.S. EPA, 1998). However, these stereological data reflect a single cohort of exposed animals, and the study deficiencies described above limit the ability to attribute the results to formaldehyde exposure alone. In addition, the limited data supporting these effects were derived from studies only testing high-level formaldehyde exposure (i.e., well above levels demonstrated to cause noncancer effects in the respiratory system; see Sections 3.2.1−3.2.4), introducing additional uncertainties. Therefore, because of the possibility of long-lasting or permanent changes to the brain following developmental exposure, this is an area in need of further research.

Table 3-46 Developmental neuropathology in experimental animal studies

Reference and study design | Results (percentage change from control) and exposure levels
Medium confidence
Reference: Sarsilmaz et al. (2007); Rat (Wistar); N = 3 litters (5 male pups^b^); 0, 7.38, or 14.8 mg/m^3a^; PND 1–PND 30; Test article: paraformaldehyde; Main limitations: Small sample size; potential for litter effects; note: same cohort as Aslan et al. (2006)^b^. | (Importantly, all data were analyzed on a pup basis rather than on a litter basis.)
| | | 0 | 7.38 | 14.8 | | | 0 | 7.38 | 14.8
| Total CA cell number assessed by stereology:
| at PND 30: | | 0 | −4^c^ | −22%^*^ | at PND 90: | | 0 | −9^*^ | −8%^*^
| Note: CA cell morphology was normal at PND 30 and PND 90
| CA volume assessed by stereology:
| at PND 30: | | 0 | 15^*^ | −28%^*^ | at PND 90: | | 0 | −7 | 10%
| Hemisphere volume assessed by stereology:
| at PND 30: | | 0 | −3^*^ | −7%^*^ | at PND 90: | | 0 | 24^*^ | 5%^*^
Reference: Aslan et al. (2006); Rat (Wistar); N = 3 litters (5 male pups); 0, 7.38, or 14.8 mg/m^3a^ PND 1−PND 30; Test article: paraformaldehyde; Main limitations: Small sample size; potential for litter effects; note: same cohort as Sarsilmaz et al. (2007)^b^ | (Importantly, all data were analyzed on a pup basis rather than on a litter basis.)
| | | 0 | 7.38 | 14.8 | | | 0 | 7.38 | 14.8
| Total DG cell number assessed by stereology:
| at PND 30: | | 0 | 3 | 0% | at PND 90: | | 0 | 10^*^ | −12%^*^
| Note: DG cell morphology was normal at PND 30 and PND 90.
| Volume of the DG assessed by stereology:
| at PND 30: | | 0 | 9^*^ | 8%^*^ | at PND 90: | | 0 | 13^*^ | −1%
Low confidence
Reference: Songur et al. (2003); Rat (Wistar); N = 3 litters (6 male pups); 0, 7.38, or 14.8 mg/m^3a^; PND 1−PND 30; Test article: paraformaldehyde; Main limitations: Small sample size; potential for sampling bias and litter effects. | (Importantly, all data were analyzed on a pup basis rather than on a litter basis.)
| | at PND 30 | | | at PND 60 | | | at PND 90
| | 0 | 7.38 | 14.8 | 0 | 7.38 | 14.8 | 0 | 7.38 | 14.8
| CA1 pyknotic neurons: | 0 | 59^*^ | 74%^*^ | 0 | 5 | 54% | 0 | 20 | −6%
| CA2 pyknotic neurons: | 0 | 322^*^ | 336%^*^ | 0 | 65^*^ | 72% | 0 | 18 | 9%
| CA3 pyknotic neurons: | 0 | 273^*^ | 291%^*^ | 0 | 128 | 60%^*^ | 0 | 60 | −19%
| Body weight: | 0 | −12^*^ | −21%^*^ | 0 | −4 | −9%^*^ | 0 | −2 | −5%

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: DG = dentate gyrus; PND = postnatal day; CA = cornu ammonis.

* p < 0.05 versus control exposure; formaldehyde levels are underlined.

a Formaldehyde levels in the study (converted to mg/m3 from ppm) were interpreted from the methods to represent the achieved mean analytical levels, although the range of measured concentrations was not reported.

b Sex and cohort information provided to EPA by personal communication (Kaplan, 2012, 2014).

c Indicated as −19% by study authors in text but estimated by EPA at −4% from data displayed graphically.

##### Neural sensitization

Research suggests that formaldehyde exposure might induce sensitization-like properties in neuronal networks (Usanmaz et al., 2002; Sorg et al., 1998; Sorg and Hochstatter, 1999; Sorg et al., 2001b; Sorg et al., 2004; Sheveleva, 1971) (see Table 3-47). Behavioral sensitization in animals can be initiated by drugs affecting the mesolimbic dopamine system (e.g., cocaine, morphine). Although the mechanisms are not fully understood, repeated, low-level exposures to certain chemicals and other stimuli have been hypothesized to cause a persistent modification to brain signaling, possibly due to altered dopamine levels in limbic circuits (Bell et al., 1992; Bell et al., 1999; Antelman et al., 1980). Subsequent re-exposure to the conditioned chemical or stimulus, or challenge with other sensitizing agents, may result in amplified neural responses. These responses can be manifest as, for example, increased impulsivity, motor activity, or CNS excitability.

Possible sensitization manifest as amplified cocaine-induced locomotor activity and conditioned fear responses, as well as disrupted sleep patterns, has been reported by one group of researchers following repeated exposure to formaldehyde at 1.23−2.46 mg/m^3^ (Sorg et al., 1998; Sorg and Hochstatter, 1999; Sorg et al., 2001b; Sorg et al., 2004). In the study interpreted with the highest confidence (medium confidence), although cross-sensitization to cocaine was not observed in female rats exposed to formaldehyde for 7 days, 4 weeks of exposure led to increased cocaine-induced vertical activity (with no difference in horizontal activity) when tested at 2−4 days (early withdrawal) and 4−6 weeks (late withdrawal) after cessation of exposure (Sorg et al., 1998). Sleep-wakefulness patterns, which are regulated in part by dopaminergic signaling (Dzirasa et al., 2006), were disrupted in male rats (females were not tested) after a 1−week withdrawal from formaldehyde inhalation (Sorg et al., 2001b); however, these results were limited by incomplete reporting (see Table 3-47). The study authors hypothesized that formaldehyde exposure may be causing a persistent stress response in the animals.

Several weeks following exposure to ≥1.23 mg/m^3^ formaldehyde for 20 days, rats previously trained in a fear conditioning paradigm (a neutral odor was paired with footshock) tended to spend more time immobilized (“freezing”) in the presence of the odor than did air-exposed controls, although these differences were not statistically significant (Sorg and Hochstatter, 1999). The authors concluded that the formaldehyde-treated rats had more difficulty than controls in extinguishing the fear response to the conditioned odor; however, as these changes were noted in response to odor cues, it is unclear whether formaldehyde preconditioning may have altered the sensitivity of the respiratory tract to odor. Overt damage of the nasal mucosa is not expected at these formaldehyde levels, and airway irritation at these levels is expected to be resolved two weeks after exposure (see Section 3.2.1), making causation by physical irritation unlikely. As these data could be related to observations suggesting increased anxiety following exposure (as discussed in the next subsection), the results identify the need to systematically test whether formaldehyde inhalation preconditioning influences responses related to limbic system function using olfactory-independent stimuli, and to compare any findings with responses caused by other stressors (e.g., restraint stress; chemicals with strong irritant odors, but no CNS action).

Equivocal evidence of increased CNS excitability following formaldehyde exposure has been reported in a few studies. Proconvulsant activity following acute formaldehyde exposures in mice was observed at 2.21−7.87 mg/m^3^ (Usanmaz et al., 2002), but not at higher exposure levels or when formaldehyde was administered for longer durations (2−3 weeks). A critical component of sensitization was not included in this study, namely, a period of latency between the stimulus and challenge. These data are difficult to interpret because of an inability to distinguish between a “wet-dog shake” due to an irritating odor and that due to a proconvulsive movement. Changes in pentylenetetrazole-induced seizures reported by Usanmaz et al. (2002) were also not easily interpreted, as no discernible pattern could be identified (e.g., seizure incidence was decreased at 18.2 mg/m^3^ and seizure intensity was increased at 2.21 mg/m^3^). In a developmental study, exposed pregnant dams displayed a significant reduction (12%) in the threshold of neuromuscular excitability at 4.92 mg/m^3^, whereas neuromuscular excitability was unchanged in rat offspring exposed in utero (Sheveleva, 1971). However, the details of the study methods, including latency between exposure and testing in dams, were not provided. It is unclear whether reflex bradypnea-related responses would affect these types of measures (e.g., via transient tissue hypoxia). No other developmental studies examining these types of effects have been identified. Overall, the data indicate the potential for an effect, but the evidence is insufficient to conclude that formaldehyde exposure causes neural excitation or acts as a proconvulsant.

In some studies, it is unclear how the observed sensitization-type responses can be fully separated from potential confounders, such as responses due to irritation (the levels used are likely to elicit some irritant aversion responses) or sensitivity to the formaldehyde odor. Odor detection and irritation responses in rodents and humans differ. In general, odor detection of formaldehyde occurs at slightly lower concentrations than irritation-related responses, with human thresholds reported at 0.068−0.135 mg/m^3^ (Berglund and Nordin, 1992; Berglund et al., 2012). An alternative explanation for some of the observed effects is that formaldehyde exposure, and the irritation associated with exposure, is uncontrollable or inescapable, which has the potential to modify stress and brain reward responses (Sorg et al., 1996). This is in contrast to situations of controllable stress expected to be encountered by formaldehyde-exposed humans. Additionally, explanations for sex-dependent differences in potential sensitization responses have yet to be explored. Overall, the human relevance of, and the formaldehyde-independent contributions to, the observed sensitization responses in rodents require additional research, including studies clarifying human sensitization-type responses to chemical irritants and well-controlled animal studies designed to mimic the human condition.

Table 3-47 Neural sensitization in experimental animal studies

Reference and study design | Results^a^ and exposure levels
Medium Confidence
Reference: Sorg et al. (1998) Rat (Sprague-Dawley); N = 15−16 (7d) or 20−24 (20 d) females 0 or 1.23 mg/m^3b^ [Actual^c^: 0 or 0.779−1.76] 7 or 20 days (5 days/week) Test article: Paraformaldehyde Main limitations: Blinding NR; description of methods incomplete. Main limitations: Blinding NR; description of methods incomplete. | Cocaine-induced vertical activity following 20-day exposures:
| | | | | | Early withdrawal^d^ | | | | Late withdrawal
| Saline-induced activity (counts): | | | | | 333 | | 333 | | 231 | | 231
| Cocaine-induced activity (counts): | | | | | 1,233 | | 3,467^*^ | | 1,983 | | 3,372^*^
| Percentage change in activity by cocaine: | | | | | 370% | | 1,040%^*^ | | 858% | | 1,460%^*^
| No changes in cocaine-induced activity were noted after 7 days of exposure and no changes in horizontal activity were noted after 20 days of exposure.; No changes in nociception (hot plate test) were noted after 7 or 20 days of exposure.
Low Confidence
Reference: Sorg et al. (2004); Rat (Sprague Dawley); N = 7-8/sex 0 or 2.46 mg/m^3b^; [Actual: 0 or 2.66]; 20 days (5 days/week); Test article: Paraformaldehyde; Main limitations: Unclear influence of changes in olfactory detection. | Freezing responses to a conditioned stimulus (CS, odor)^h^ in males:
| | Day 1 | | Day 2 | | Day 3 | | Day 4 | | Day 5 | | Renewal^i^
| | 0 | 2.46 | 0 | 2.46 | 0 | 2.46 | 0 | 2.46 | 0 | 2.46 | 0 | 2.46
| Unpaired: | 0 | 64%^*^ | 0 | 19% | 0 | 7% | 0 | 76%^*^ | 0 | 0% | 0 | 86%
| Paired: | 0 | 26% | 0 | 12% | 0 | 5% | 0 | 22% | 0 | 50%^*^ | 0 | 47%
| No changes observed in response to the context alone (footshock or novel).; No change in female conditioned fear behaviors (to context or CS).
Reference: Usanmaz et al. (2002); Mouse (Balb/C); N = 6 Sex NR 0, 2.21, 3.94, 7.87, 11.9, or 18.2 mg/m^3j^: 3 hours; 0 or 3.94 mg/m3: 2 weeks; 0 or 2.46 mg/m3: 3 weeks; Test article: Paraformaldehyde; Main limitations: Tested immediately after exposure; blinding NR. | CNS excitability after a 3-hour exposure:
| | | | | | 0 | | 2.21 | 3.94 | 7.87 | 11.9 | 18.2
| Percentage incidence of wet-dog shake^k^: | | | | | 0 | | 63^*^ | 67^*^ | 60^*^ | 25 | 17%
| Percentage incidence of seizures^l^: | | | | | 91 | | 82 | ND | 60 | ND | 33%^*^
| Seizure intensity (median vales): | | | | | 4 | | 6^*^ | ND | 4 | ND | 1
| Seizure threshold (seconds to onset): | | | | | 74 | | 83 | ND | 104 | ND | 110%
| No significant effects on seizure mortality.; No significant effects on CNS excitability after 2−3 weeks of exposure.
Reference: Sorg et al. (2001b); Rat (Sprague-Dawley); N = 6/sex 0 or 2.46 mg/m^3b^; [Actual: not reported]; 20 days (5 days/week); Test article: Paraformaldehyde; Main limitations: Description of methods incomplete; no preformaldehyde exposure comparisons. | Sleep patterns, as assessed by EEG/EMG in Males 7 days after exposure:
| [Dark: 1−12h/Light: 13−24h phase^g^]: | | | | | 1–6h | | 7–12h | | 13–18h | | 19–24h
| | | | | | 0 | 2.46 | 0 | 2.46 | 0 | 2.46 | 0 | 2.46
| Number of waking episodes: | | | | | 0 | −30% | 0 | −25% | 0 | −16% | 0 | −18%
| Number of NREMS episodes: | | | | | 0 | −25% | 0 | −21% | 0 | −10% | 0 | −18%
| Duration of waking episodes: | | | | | 0 | 37% | 0 | 59% | 0 | 9% | 0 | 12%
| *Significant treatment effects noted for each measure above by 2−way ANOVA.; No changes in REMS episodes or duration of NREMS episodes were noted.; [Note: a 15−min challenge with 37% formalin odor abolished all differences.]
Reference: Sorg and Hochstatter (1999); Rat (Sprague-Dawley); N = 4−8 females; 0 or 1.23 mg/m^3b^; [Actual: not reported]; 20 days (5 days/week); Test article: Paraformaldehyde; Main limitations: Unclear impact of altered olfactory detection or cocaine injection; note: formalin use as an aversive odor was deemed irrelevant. | | | | | | | | | | 0 | | 1.23
| Cocaine (10 mg/kg)-induced horizontal activity (as percentage change in induced activity):
| Cocaine-induced activity 2−4 days after air or formaldehyde, as compared to cocaine-induced activity prior to exposure: | | | | | | | | | 198 | | 407%^*^
| Fear-conditioned responses to odor (as percentage change from nonshocked) ^f^ :
| Freezing in the context used for shock training: | | | | | | | | | 433^*^ | | 476%^*^
| Freezing with the conditioned odor 2 days later: | | | | | | | | | 45 | | 127%^*^
| Freezing with the conditioned odor 12 days later: | | | | | | | | | 54 | | 181%^*^
| *p < 0.05, as compared to no shock condition in the same exposure group (t-test).; [Notes: Statistically significant differences in direct comparisons of the control and HCHO pre-exposed groups were not observed for any fear conditioning tests (N = 4).]
Reference: Sheveleva (1971); Rat (Strain NR); N = 15/sex; 0, 0.492, or 4.92 mg/m^3e^; [Actual: 0, 1.24, 3.09, or 6.20]; GD 1−GD 19; Test article: Not reported; Main limitations: Test article and endpoint evaluation methods NR. | | | | | | 0 | | 0.492 | | 4.92
| Neuromuscular excitability in dams: | | | | | 0 | | −7 | | −19%^*^
| No changes in offspring neuromuscular excitability.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: GD = gestational day; NREMS = nonrapid eye movement sleep; CS = conditioned stimulus; ND = not determined; NR= not reported; EEG/EMG= electroencephalogram/electromyelogram; CNS = central nervous system.

* p < 0.05 vs. control exposure unless otherwise indicated; formaldehyde levels are underlined.

a Data presented as percentage change from control, unless otherwise indicated.

b Formaldehyde levels in the study converted to mg/m^3^ from ppm.

c Actual mean analytical concentrations achieved.

d 2–4 days after discontinuing exposure, rats were given cocaine and evaluated for 2 hr (early withdrawal); an additional cocaine challenge and locomotor assessment were conducted 4−6 week later (late withdrawal).

e Formaldehyde levels in the study (converted to mg/m^3^ from mg/L) represented the achieved analytical levels.

f Context = in the context the shock was delivered, rats receiving shock training vs. those not shocked were compared at 1 day after training; conditioned odor = comparison as in “context” 2 or 12 days after training except in a novel context and with the odor used for shock training (orange oil) present. Values and statistical analyses are compared against nonshocked rats within the same treatment group.

g Data were recorded for 6-hour periods beginning at dark phase for 24 hours; percentage change from air controls for each period is presented; air and formaldehyde groups were significantly different by two-way ANOVAs.

h Several weeks after treatment an orange oil odor (CS) was either Paired (with CS presentation) or Unpaired (separately and randomly from CS presentation) with footshocks, then testing performed over subsequent days

i CS presented in a second, completely novel context.

j Formaldehyde levels in the study (converted to mg/m^3^ from ppm) were interpreted from the methods to represent the achieved mean analytical levels, although the range of measured concentrations was not reported.

k Wet-dog shake, a possible pro-convulsive sign, is a shuddering motion in rodents that can be induced pharmacologically with agents that affect glutamatergic and/or serotonergic signaling.

i Seizures were induced by injection of pentylenetetrazole.

##### Tests of general motor-related behaviors

This section encompasses a range of behavioral tests examining general locomotion (without pharmacological manipulation) as the output. These tests span a range of test environments and testing conditions, and the observed responses often involve contributions from multiple specific behavioral processes (e.g., motor function, anxiety, arousal, olfaction, acclimation to the test environment, etc.) that can be difficult to disentangle. Motor-related tests designed to examine learning and memory processes are discussed separately in the next section.

Animal studies that included protocols of sufficient duration to specifically assess changes in motor function (Sorg et al., 1998; Sorg et al., 2001b) either did not observe effects of formaldehyde inhalation alone (Sorg et al., 1998) or were complicated by irritant effects when tested during exposure (Sorg et al., 2001b). However, open field activity testing following formaldehyde exposure revealed decreased ambulatory activity in rats and mice, as well as elevated anxiety and reduced habituation to the test environment in nearly all available studies (Usanmaz et al., 2002; Sheveleva, 1971; Malek et al., 2003a, b, 2004; Boja et al., 1985) (see Table 3-48). Open field testing is a commonplace test that can be standardized and reproducible (Broadhurst, 1969), but which often involves a somewhat arbitrary interpretation of different behavioral features. The short testing duration used in open field tests (typically 3−5 minutes) is not of sufficient length to accurately assess motor function, and the results are also affected by the initial anxiety of the animals to the novel test environment. Thus, with these tests (which vary by laboratory), it can be difficult to separate changes in motor function and interpretation of olfactory and visual cues from changes due to exploration of a novel environment and anxiety due to open spaces and bright light (e.g., increased anxiety correlates with decreased ambulation in these tests). A second test (typically 24 hours later) measures the level of habituation or learned familiarity to the test environment. Due primarily to prominent exposure-quality issues (Sheveleva, 1971; Malek et al., 2003a, b, 2004) or significant study design concerns (Usanmaz et al., 2002; Sheveleva, 1971; Boja et al., 1985), all of the data suggesting effects of exposure on motor-related behaviors are derived from low confidence studies (see Appendix A.5.7), limiting their interpretability.

Consistent decreases in open field locomotor activity in male mice and rats of both sexes were observed at formaldehyde concentrations as low as 0.123 mg/m^3^ (with rats exhibiting enhanced sensitivity) when assessed shortly after a single, acute formaldehyde exposure (Malek et al., 2003a, b, 2004) or after exposure for 1 week (Li et al., 2016); however, these studies employed formalin exposures. From the current studies it remains unclear whether these changes persist more than a few hours after exposure, noting that motor activity testing (not open field tests) did not reveal changes several weeks after exposure (Sorg et al., 1998). A portion of this immediate response in male mice may be due to increased anxiety, as decreases in crossed inner squares occurred at notably lower levels than decreases in crossed peripheral squares (anxious animals tend to spend less time in the open and bright areas at the center of the field), suggesting an elevated stress response after acute exposure (Malek et al., 2004); however, this increased anxiety was not confirmed in a second, short-term study (Li et al., 2016), which actually reported evidence of a decrease in anxiety in both open field and elevated plus maze tests at 1.23 mg/m^3^. Although, no changes were observed at 2.46 mg/m^3^ and changes in plus maze activity were not observed in rats that were similarly exposed (Sorg et al., 1998). Perhaps relatedly, short-term exposure of mice to ≥1 mg/m^3^ resulted in dose-dependent increases in immobility time in the forced swim test (Li et al., 2016), a stress-related test of “behavioral despair” (Porsolt et al., 1977). When habituation to the open field was tested 24 hours after exposure, formaldehyde-treated rats and mice did not demonstrate the same degree of habituation as control animals (Malek et al., 2003a, 2004). In male rodents, the degree of habituation was reduced compared to controls. In contrast, formaldehyde-treated female rats demonstrated robust increases (50−150%) in activity at all formaldehyde exposure levels (≥1.23 mg/m^3^), suggesting not only reduced habituation, but also delayed hyperactivity in these animals. These mixed results suggest a general effect on behavior across a range of tests of general motor-related behaviors, but the specifics of this effect(s) remain difficult to interpret and require clarification in studies with better-controlled formaldehyde exposures.

A serious concern that changes may be due to irritation and related phenomena (e.g., reflex bradypnea; distractibility) is raised for three of the studies which evaluated behaviors during or immediately after exposure to formaldehyde at concentrations expected to cause irritation (Usanmaz et al., 2002; Boja et al., 1985). Decreased activity from 0 to 24 hours after exposure to 6.15 mg/m^3^ formaldehyde was reported using a minimally informative protocol developed for observations of rat pups (Boja et al., 1985), with activity defined as the percentage of time “active” (i.e., not sleeping or immobile). Consistent with the pattern of alterations to habituation reported by (Malek et al., 2003a, 2004), after several days of daily exposure and activity testing, vertical activity measured during exposure to 2.46 mg/m^3^ formaldehyde was depressed in male rats (on exposure days 12−20) and increased in female rats (on exposure days 5 and 20), as compared to controls (Sorg et al., 2001b). Usanmaz et al. (2002) noted unexplainable formaldehyde sensitivity (gastrointestinal impairment and decreased weight gain), causing them to discontinue the study, at exposures as low as 2.5 mg/m^3^ for 3 weeks, which would be expected to confound their findings of decreased activity. Owing primarily to the timing of the behavioral tests, none of the observed changes in activity can be clearly attributed to formaldehyde-induced effects on the nervous system.

Reduced spontaneous mobility at PND 30 was observed in pups exposed in utero to 0.492 or 4.92 mg/m^3^ (Sheveleva, 1971). In contrast, concentration-related increases in mobility were observed in these pups at PND 60 (an increased level of spontaneous mobility was also observed in dams at 4.92 mg/m^3^), with the female pups exhibiting enhanced sensitivity. Increases in activity which persist into adulthood following developmental exposure are of concern. However, the methodology was insufficiently described and the significance of these formaldehyde-induced, bidirectional changes in the activity of young animals, which were dependent either on the delay between exposure and testing or the postnatal age at testing, is unclear.

Overall, the data from basic tests of motor-related behaviors suggest an effect in formaldehyde-exposed rodents. This response may be short lived, and, at least in open field tests, rats seem to be more sensitive to changes following formaldehyde exposure than mice (which would be consistent with the known toxicokinetic differences across species; see Appendix C.1) and females seem to exhibit a different pattern of responses than their male counterparts. Somewhat differing results across some of the studies, particularly in tests other than open field activity (i.e., elevated plus maze and forced swim test), together present a complicated picture of these potential effect(s). More importantly, however, no studies using methanol-free formaldehyde and other appropriate methodology were available to clarify and confirm the findings of behavioral changes from this set of low confidence studies.

Table 3-48 Tests of motor-related behaviors in experimental animal studies

Reference and study design | Results^a^ and exposure levels
Medium confidence (activity); low confidence (elevated plus maze)
Reference: Sorg et al. (1998); Rat (Sprague-Dawley); N = 15−24 females; 0 or 1.23 mg/m^3b^; [Actual^c^: 0 or 0.779−1.76]; 7 or 20 days (5 days/week); Test article: Paraformaldehyde; Main limitations: Description of methods incomplete; activity could be affected, and plus maze data are likely affected, by prior manipulations; total plus maze activity NR; blinding NR. | No change in horizontal or vertical activity were noted following saline injections 2−4 days or 4−6 weeks after discontinuing formaldehyde exposures.; Note: activities were measured over a 2−hour period after allowing the rats to acclimate to the test environment.; No statistically significant changes in elevated plus maze performance were noted.; Note: percentage open arm entries and percentage time spent in open arms were decreased 24 and 39%, respectively after 7 days [p = 0.06 for percentage time]; percentage time in open arms was increased 21% after 20 days, but this did not approach statistical significance.
Low confidence
Reference: Li et al. (2016); Mouse (Kunming: outbred Swiss albino); N = 15 males; 0, 1.23, or 2.46 mg/m^3c^; [Actual: levels confirmed]; 7 days (2 hours/day); Test article: Formalin; Main limitations: Formalin; blinding NR for tests other than forced swim; possible influence of multiple behavioral tests in the same animals. | | | 0 | 1.23 | 2.46 | | 0 | 1.23 | 2.46
| Open Field Activity (2-hr postexposure): | | | | | Elevated Plus Maze (after open field):
| Total Distance: | | 0 | −3.15 | −18.7^*^ | Total Distance: | 0 | 0.70 | −3.00
| Total Crossings: | | 0 | −4.02 | −20.9^*^ | Number of Entries: | 0 | −14.5 | −12.1
| Percentage Center Time: | | 0 | 39.0^*^ | −11.5 | Percentage Open Arm Time: | 0 | 20.9^*^ | −4.33
| Forced Swim (after plus maze):
| Immobility Time: | | 0 | 42.3 | 87.6^*^
| Note: Statistically significant differences in body-weight gain were observed at 2.46 mg/m^3^ (−3.7%, as compared to + 1.82% in controls).
Reference: Malek et al. (2003a); Rat (LEW.1K); N = 15/sex; 0, 1.23, 3.08, or 6.15 mg/m^3c^; [Actual: 0, 1.24, 3.09, or 6.20]; 2 hours; Test article: Formalin; Main limitation: Formalin.; [Note: an excessive level of variability was noted for this study, possibly due to an erroneous indication of data as Mean ± SE in this study, in contrast to Mean ± SD in the other studies by (2003b (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=626722), c (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=626536), 2004 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=626720)).] | | Males | | | | Females
| | 0 | 1.23 | 3.08 | 6.15 | 0 | 1.23 | 3.08 | 6.15
| Open field activity and behaviors at 2 hours postexposure:
| Locomotion: | 0 | −63^*^ | −22^*^ | −41%^*^ | 0 | −72^*^ | −30^*^ | −36%^*^
| Grooming: | 0 | −47 | −23^*^ | −34%^*^ | 0 | 4 | −17^*^ | −62%^*^
| Air sniffing: | 0 | 103^*^ | 118^*^ | 104%^*^ | 0 | 1 | −23^*^ | 22%^*^
| Floor sniffing: | 0 | 105^*^ | 51^*^ | 84% | 0 | −2 | 56 | 79%
| Wall climbing: | 0 | −22^*^ | −22^*^ | −26%^*^ | 0 | −8 | −14 | 16%
| Rearing: | 0 | 28 | 32 | 2% | 0 | 58^*^ | 74^*^ | 42%
| Note: No changes in defecation.
| Habituation to the open field at 26 hours postexposure (Trial 2/Trial 1 ^h^ ):
| Locomotion: | −80 | −44 | −35^*^ | −21%^*^ | −78 | 140^*^ | 42^*^ | 38%^*^
| Air sniffing: | 161 | −31^*^ | −13^*^ | 12%^*^ | 78 | 48^*^ | 174^*^ | 43%
| Climbing: | 95 | −10^*^ | −14^*^ | 38%^*^ | 73 | 118 | 105 | 46%
| Rearing: | −14 | 6^*^ | 9^*^ | 24%^*^ | 34 | 3 | 6^*^ | −8%
| Note: No consistent changes in grooming, floor sniffing, or defecation.
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | | Males | | | | Females
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | | 0 | 0.123 | 0.615 | 6.15 | 0 | 0.123 | 0.615 | 6.15
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Open field activity and behaviors at 2 hours postexposure:
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | locomotion: | 0 | −17^*^ | −48^*^ | −65%^*^ | 0 | −5 | −19^*^ | −39%^*^
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Air sniffing: | 0 | 8^*^ | −22^*^ | −55%^*^ | 0 | 21^*^ | 14^*^ | −11%^*^
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Floor sniffing: | 0 | −23^*^ | −39^*^ | −64%^*^ | 0 | −5 | −23^*^ | −27%^*^
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Wall climbing: | 0 | 21^*^ | −55^*^ | −72%^*^ | 0 | 54^*^ | −4 | −34%^*^
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Rearing: | 0 | −57^*^ | −75^*^ | −59%^*^ | 0 | 44^*^ | −35^*^ | −24%
Reference: Malek et al. (2003b); Rat (LEW.1K); N = 10/sex; 0, 0.123, 0.615 or 6.15 mg/m^3c^; [Actual: 0, 0.160, 0.590, or 6.37]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Note: No consistent changes in grooming or defecation.
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | | Open field activity and behaviors at 2 hours postexposure: | | | | Habituation to the open field at 26 hours postexposure:
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | | 2 hr (Percentage control) | | | | 26 hr (Trial 2/Trial 1^h^)
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | | 0 | 1.35 | 2.83 | 6.40 | 0 | 1.35 | 2.83 | 6.40
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Crossed inner squares: | 0 | −26^*^ | −38^*^ | −53%^*^ | −70 | −62 | −57 | −40%
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Crossed outer squares: | 0 | 5 | −12 | −49%^*^ | −24 | −25 | −10 | 41%
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Total crossed squares: | 0 | −7 | −22^*^ | −51%^*^ | −41 | −36 | −24 | 15%
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Air sniffing: | 0 | 11 | −16^*^ | −58%^*^ | −29 | −38 | −23 | 52%
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Floor sniffing: | 0 | 26^*^ | 2 | 9% | 3 | −40^*^ | −38^*^ | −23%^*^
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Grooming: | 0 | −11 | −11 | −18% | 5 | 96^*^ | 45^*^ | 82%^*^
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Rearing: | 0 | −22^*^ | −37^*^ | −44%^*^ | 3 | −11^*^ | 8^*^ | 21%^*^
Reference: Malek et al. (2004); Mouse (AB); N = 20 Males; 0, 1.35, 2.83 or 6.40 mg/m^3c^; [Actual: 0, 1.37, 2.84, or 6.64]; 2 hours; Test article: Formalin; Main limitation: Formalin. | Note: No consistent changes in wall climbing or defecation.
Reference: Usanmaz et al. (2002); Mouse (Balb/C); N = 6 (sex NR); 0, 2.21, 3.94, 5.54, 7.87, 11.9, or 18.2 mg/m^3^ ^j^: 3 hours; 0 or 2.46 mg/m^3^: 1 or 3 weeks; 0, 2.46, or 3.94 mg/m^3^: 2 weeks; Test article: Paraformaldehyde; Main limitations: Tested immediately after exposure; blinding NR. | | | 0 | 2.21 | 3.94 | 5.54 | 7.87 | 11.9 | 18.2
| Open field activity immediately after a 3-hour exposure:
| Horizontal activity: | | 0 | −10 | −16 | −28 | −35^*^ | −69^*^ | −91%^*^
| Vertical activity: | | 0 | −26^*^ | −43^*^ | −48^*^ | −48^*^ | −83^*^ | −88%^*^
| Open field activity^k^ and body-weight gain after 1- to 3-week exposures:
| | | 1 week | | 2 weeks | | | 3 weeks
| | | 0 | 2.46 | 0 | 2.46 | 3.94 | 0 | 2.46
| Horizontal activity: | | 0 | −28%^*^ | 0 | −3 | −40%^*^ | 0 | −23%
| Vertical activity: | | 0 | −37%^*^ | 0 | −1 | −44%^*^ | 0 | −32%^*^
| Body-weight gain: | | 0 | 33% | 0 | 0 | −150%^*^ | 0 | −280%^*^
Reference: Sorg et al. (2001b); Rat (Sprague-Dawley); N = 7−8/sex; 0 or 2.46 mg/m^3c^; [Actual: not reported]; 20 days (5 days/week); Test article: Paraformaldehyde; Main limitations: Activity tested during exposure; description of methods incomplete. | Total vertical activity during formaldehyde exposure:; Males: ↓ at exposure days 12−20 (−25 to −55%^*^); Females: ↑ at exposure days 5 (133%^*^) and 20 (98%^*^)
Reference: Boja et al. (1985); Rat (Sprague Dawley); N = 8 males; 0 or 6.15^b^ mg/m^3c^; [Actual^d^: not reported]; 1−2 days (switching paradigm); Test article: Paraformaldehyde; Main limitations: Tested immediately after exposure; uncommon protocol. | Percentage time “active” versus “inactive”^e^ during exposure relative to air controls:
| | | | | | | at 30 min. | at 60 min. | at 120 min.
| Day 1 HCHO (Day 1 exposed): | | | | | | −34%^*^ | −66%^*^ | −77%^*^
| Day 2 HCHO (Day 1 and 2 exposed): | | | | | | −76%^*^ | −70%^*^ | 24%
| Day 2 HCHO (only Day 2 exposed): | | | | | | −58% | −80% | 122%
| 24h post HCHO (only Day 1 exposed): | | | | | | −30% | −80% | 72%^f^
| Boja et al. (1985)
Reference: Sheveleva (1971); Rat (Strain NR); N = 15/sex; 0, 0.492, or 4.92 mg/m^3i^; [Actual: 0, 1.24, 3.09, or 6.20]; GD 1–GD 19; Test article: Not reported; Main limitations: Test article and endpoint evaluation details NR. | | | | Males | | | Females
| | | | 0 | 0.492 | 4.92 | 0 | 0.492 | 4.92
| Spontaneous mobility in offspring and dams:
| at PND 30: | | | 0 | −48^*^ | −2% | 0 | −36^*^ | −44%^*^
| at PND 60: | | | 0 | 16 | 32% | 0 | 42 | 291%^*^
| in dams: | | | NA | NA | NA | 0 | −46 | 89%^*^

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: HCHO = formaldehyde; SE = standard error; SD = standard deviation; GD = gestational day; NR= not reported; PND = postnatal day.

* p < 0.05 vs. control exposure; formaldehyde levels are underlined.

a Data presented as percentage change from control, unless otherwise indicated.

b Additional exposure groups of 12.3 and 24.6 mg/m^3^ were indicated, but data were not reported and thus, not included.

c Formaldehyde levels in the study converted to mg/m^3^ from ppm.

d Actual mean analytical concentrations achieved.

e Active (e.g., grooming, eating, climbing, ambulating, etc.) versus inactive (i.e., immobile, sleeping).

f Statistical comparisons to air-air group not performed.

g Locomotion = crossed squares; M = changes were observed in males; F = changes were observed in females.

h Values presented as Trial 2 (26 hr) vs. Trial 1 (2 hr) performance in same group; * for comparisons within Trial 2.

i Formaldehyde levels in the study (converted to mg/m^3^ from mg/L) represented the achieved analytical levels.

j Formaldehyde levels in the study (converted to mg/m^3^ from ppm) were interpreted from the methods to represent the achieved mean analytical levels, although the range of measured concentrations was not reported.

k Open field activity in the short-term studies is inferred to have been conducted immediately following exposure.

##### Tests of learning and memory

Five studies have examined the effects of inhaled formaldehyde on learning and memory processes in experimental animals (see Table 3-49). All of the studies are expected to have significant coexposures due to the formaldehyde generation methods (see Appendix B.3.7), and thus, the effects cannot be attributed to formaldehyde inhalation alone. In addition, many of the dose-response relationships are difficult to interpret and the results are occasionally inconsistent.

Decreased performance in short-term spatial memory tasks following exposure to formaldehyde has been observed in rats across two low confidence studies from coauthors in the same research institute (Pitten et al., 2000; Malek et al., 2003c), with supportive, related findings from three low confidence mouse studies (Mei et al., 2016; LICM, 2008; Li et al., 2016). These testing paradigms involve components of memory, orientation, reward seeking, stress, olfactory and visual information processing, and motor function. In the rat studies, increased error rate and increased latency in a water maze were observed after short-term exposures to ≥0.123 mg/m^3^ and ≥0.615 mg/m^3^, respectively (Malek et al., 2003c), although the results were not entirely consistent across all trial days. Similarly, very brief (10-minute) formaldehyde exposures over a prolonged duration (90 days) resulted in an increased number of errors and longer running times in a land-based maze at ≥3.06 mg/m^3^ (Pitten et al., 2000), with an increasing magnitude of change with increasing trial days, which suggests an additive effect of exposure. In general, excluding the latency measures reported by Malek et al. (2003c), all exposed rats were equally impaired across a broad range of exposures; no explanation for this lack of a dose-response relationship is presently available. These observations are supported by potentially related findings in mice exposed for 1 week to similar levels of formaldehyde (i.e., 2.46 to 3 mg/m^3^); specifically, exposed mice exhibited decreased performance in the Morris water maze (Mei et al., 2016) and decrements in a test of recognition memory, the novel object test (Li et al., 2016). However, it is difficult to attribute these decrements to formaldehyde exposure due to notable methodological limitations (e.g., the use of formalin and the lack of observer blinding for these nonautomated measures raise substantial concerns). In addition, the data from both studies suggest possible complicating effects on behaviors other than learning or memory in the mice exposed to formaldehyde [i.e., in Mei et al. (2016), exposed mice did not exhibit improved performance across training trials and swimming tracks suggest that they avoided the target quadrant completely during the probe trial; in Li et al. (2016), even in the absence of a novel object, exposed mice spent approximately half the time exploring objects during training than did controls]. Although vision and olfaction were not evaluated in these rodent studies, possible effects on these functions are not expected to influence performance in the studies by Malek et al. (2003c), Mei et al. (2016), and Li et al. (2016), or by Pitten et al. (2000), as assessments occurred 2−3 or 22 hours after exposure(s), respectively. In contrast, supportive observations in mice (LICM, 2008) are considered even less reliable due to the short, 30-minute delay before testing following exposure to formaldehyde and other potential contaminants (formaldehyde was released from wood baseboard) at levels that are likely to induce irritation-related responses.

In rats, the increases in maze latency are most likely reflective of the increased number of errors in treated animals as errors usually increase the distance traveled, and thus the time required, for completion of the trial. However, in the absence of data on path length or motor speed in all three of the maze-based studies, it is unclear whether hyperactivity of the formaldehyde-exposed animals may have been present (e.g., increased swim time and increased number of errors due to exposed animals swimming faster in circular or back-and-forth patterns). In the study by Malek et al. (2003c), increased swim speed is indeed evident at 0.123 mg/m^3^ in females: despite making approximately four more errors than control rats on trial days 4, 5, and 8, they still had significantly shorter swimming times. Recovery following exposure was only assessed by Pitten et al. (2000), who observed that performance was still impaired 4 weeks after exposures had ended.

While the study authors interpreted these results to suggest deficits in the retention of a previously learned task or in remembering a previously explored object, these studies had significant methodological shortcomings. Thus, sole attribution of the decreases in performance to formaldehyde-induced impairment, and specifically to impairment of memory or orientation, cannot be concluded. Although two developmental studies evaluating learning and memory processes following formaldehyde exposure were identified (Senichenkova, 1991a; Liao et al., 2010), data from these studies were not considered useful for the purposes of hazard characterization (see Appendix B.3.7). Overall, while the available data suggest a potential effect on behavior in tests of learning and memory, which may or may not reflect effects on those specific cognitive processes, no studies using methanol-free formaldehyde and other more appropriate methodology were available to clarify and confirm the findings of behavioral changes from this set of low confidence studies.

Table 3-49 Tests of learning and memory in experimental animal studies

Reference and study design | Results (as indicated) and exposure levels
Low confidence
Reference: Li et al. (2016); Mouse (Kunming: outbred Swiss albino); N = 15 males; 0, 1.23, or 2.46 mg/m^3a^; [Actual: levels confirmed]; 7 days (2 hours/day); Test article: Formalin; Main limitations: Formalin; blinding NR; possible influence of multiple behavioral tests performed in the same animals. | | | | | | | | | | | | 0 | | 1.23 | | 2.46
| Novel Object Training and Testing (^~^ 2 days postexposure):
| Training exploration (time ± SEM) of Left identical object: | | | | | | | | | | | 94 ± 14 | | 99 ± 25 | | 55 ± 10
| Training exploration (time ± SEM) of Right identical object: | | | | | | | | | | | 98 ± 20 | | 88 ± 23 | | 51 ± 9
| Familiar object exploration (seconds) 24-hr posttraining: | | | | | | | | | | | 69.8 | | 47.0, | | 61.8
| Novel object exploration (seconds) 24-hr posttraining (*p < 0.05 versus familiar object exploration time): | | | | | | | | | | | 149^*^ | | 103^*^ | | 41.6
| Discrimination Index [(novel object time ÷ total time) − (familiar object time ÷ total time) × 100]: | | | | | | | | | | | 43.3 | | 32.7 | | −12.0^*^
| Notes: Statistically significant differences in body-weight gain were observed at 2.46 mg/m^3^ (−3.7%, as compared to + 1.82% in controls). The study authors did not provide comparisons of total exploratory activity (Left + Right object) during training.
Reference: Mei et al. (2016); Mouse (Balb/c); N = 8 males; 0 or 3 mg/m^3a^; [Actual: confirmed, 3.04 ± 0.13 mg/m^3^]; 7 days (8 hours/day); Test article: Formalin; Main limitations: Formalin; blinding NR; details of behavioral protocols NR. | Training trials escape latency (sec.; *p < 0.05: Dunnett’s post hoc tests on ANOVA)^e^:
| | | | | | Control | | | 3 mg/m^3^
| Day 1: | | | | | 58.2 | | | 56.7
| Day 2: | | | | | 55.4 | | | 55.0
| Day 3: | | | | | 55.7 | | | 52.2
| Day 4: | | | | | 49.4 | | | 51.4
| Day 5: | | | | | 38.0 | | | 52.1^*^
| Day 6: | | | | | 36.3 | | | 50.4^*^
| Day 7: | | | | | 33.1 | | | 50.7^*^
| Probe trial test performance on Day 8 ^e^ : | | | | | | | | | | | Control | | | 3 mg/m^3^
| Mean (+ SE) swim distance (cm) in target quadrant: | | | | | | | | | | | 316 (± 42) | | | 154^*^ (± 16)
| Mean (+ SE) time (sec) in target quadrant: | | | | | | | | | | | 27.5 (± 3.4) | | | 10.0^*^ (± 0.9)
Reference: LICM (2008); Mouse (Kun Ming: outbred Swiss albino); N = 5 males; 0, 1, or 3 mg/m^3^; [Actual^a^: 0.020, 0.990, or 3.03]; 7 days beginning at ^~^PND 42; Test article: Wood baseboard; Main limitations: Undefined mixture exposure; possible impact of irritation. | | | | | | | | | | | | 0 | | 1 | | 3
| Escape latency across training trial days in the Morris water maze ^b^ :
| Latency (percentage from control for averaged trial days): | | | | | | | | | | | 0 | | 32 | | 74%^*^,^c^
| Note: Magnitude of change was unrelated to duration of exposure.
| Performance during probe trial test:
| Time spent in the target quadrant (percentage from controls): | | | | | | | | | | | 0 | | −19 | | −41%
| Note: Only controls spent significantly more time in the target quadrant.
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Latency and number of errors in a water maze:
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | | Maze errors (as #) | | | | | | | | Swim time (as percentage control)
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | | Males | | | | Females | | | | Males | | | | Females
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | | 0 | .12 | .62 | 6.6 | 0 | .12 | .62 | 6.6 | 0 | .12 | .62 | 6.6 | 0 | .12 | .62 | 6.6
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 1: | 7 | 8 | 8 | 8 | 8 | 7 | 8 | 8 | 0 | −5 | −8^*^ | 0 | 0 | −7^*^ | −6^*^ | −5^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 2: | 6 | 7 | 6 | 6 | 8 | 7^*^ | 8 | 6^*^ | 0 | −1 | 3 | 8^*^ | 0 | −4 | −2 | 4^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 3: | 5 | 5 | 6^*^ | 7^*^ | 4 | 6^*^ | 7^*^ | 8^*^ | 0 | −2 | 14^*^ | 4 | 0 | 4 | 8^*^ | −2
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 4: | 2 | 5^*^ | 5^*^ | 6^*^ | 1 | 6^*^ | 5^*^ | 6^*^ | 0 | −11 | 29^*^ | 14^*^ | 0 | −24^*^ | 16^*^ | 14^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 5: | 1 | 4^*^ | 3^*^ | 5^*^ | 1 | 4^*^ | 4^*^ | 5^*^ | 0 | −11 | −2 | 23^*^ | 0 | −13^*^ | −9 | −1
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 6: | 1 | 5^*^ | 4^*^ | 5^*^ | 0 | 5^*^ | 5^*^ | 5^*^ | 0 | 6 | 37^*^ | 111^*^ | 0 | −2 | 17^*^ | 88^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 7: | 0 | 5^*^ | 4^*^ | 5^*^ | 0 | 5^*^ | 4^*^ | 5^*^ | 0 | 6 | 38^*^ | 94^*^ | 0 | 12^*^ | 11^*^ | 62^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 8: | 0 | 3^*^ | 3^*^ | 3^*^ | 0 | 4^*^ | 3^*^ | 3^*^ | 0 | −3 | −8 | 41^*^ | 0 | −20^*^ | −8 | 15^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 9: | 0 | 3^*^ | 3^*^ | 3^*^ | 0 | 3^*^ | 3^*^ | 4^*^ | 0 | 3 | 17^*^ | 64^*^ | 0 | 18^*^ | 11^*^ | 46^*^
Reference: Malek et al. (2003c); Rat (LEW.1K); N = 15/sex; 0, 0.123, 0.615, or 6.64 mg/m^3d^; 10 days; Test article: Formalin; Main limitations: Formalin; protocol deficiencies, including blinding NR. | Day 10: | 0 | 3^*^ | 2^*^ | 3^*^ | 0 | 3^*^ | 2^*^ | 3^*^ | 0 | −3 | 21^*^ | 73^*^ | 0 | 15 | 17^*^ | 49^*^
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Latency and number of errors in a land maze:
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | | | | | | Latency (as percentage control)^g^ | | | | | | Errors (as percentage control)
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | | | | | | 0 | | 3.06 | | 5.55 | | 0 | | 3.06 | | 5.55
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 0: | | | | | 0 | | −6 | | 4% | | 0 | | −39 | | −7%
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 2: | | | | | 0 | | 8 | | 21% | | ND | | ND | | ND
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 4: | | | | | 0 | | 30 | | 51% | | 0 | | 70 | | 91%
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 6: | | | | | 0 | | 48 | | 76% | | ND | | ND | | ND
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 8: | | | | | 0 | | 75^*^ | | 113%^*^ | | 0 | | 116 | | 112%
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 10: | | | | | 0 | | 94^*^ | | 143%^*^ | | ND | | ND | | ND
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | Exposure week 12: | | | | | 0 | | 128^*^ | | 185%^*^ | | 0 | | 153^*^ | | 184%^*^
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | 2 weeks postexposure: | | | | | 0 | | 168^*^ | | 241%^*^ | | ND | | ND | | ND
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | 4 weeks postexposure: | | | | | 0 | | 215^*^ | | 303%^*^ | | 0 | | 72 | | 89%
Reference: Pitten et al. (2000); Rat (Wistar); N = 5−8/sex^f^; 0, 3.06, or 5.55 mg/m^3d^; 90 days (Note: only 10 minutes/day exposures); Test article: Formalin; Main limitation: Formalin. | No CNS pathology or changes in body weight were observed.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: SEM = standard error of the mean; PND = postnatal day; ND = not detected.

* p < 0.05 vs. control exposure (unless otherwise indicated); formaldehyde levels are underlined.

a Actual mean analytical concentrations achieved.

b Morris water maze: Four trials/day during training; Probe trial involved removal of the platform on Day 7.

c Significant differences between the 0 and 3 mg/m^3^ groups by multiple comparison testing (LICM, 2008).

d Formaldehyde levels in the study (converted to mg/m^3^ from ppm) represented the achieved analytical levels.

e Data digitized using Grab It!™, Datatrend Software.

f Male and female data were pooled for comparisons; no differences between sexes were noted.

g Average seconds estimated from points along the fitted linear regression curves presented by Pitten et al. (2000).

##### Summary of Animal Evidence Synthesis Judgments

###### Neurobehavioral Tests

The following factors were influential to the synthesis judgment that the animal studies provide slight evidence of formaldehyde exposure-induced neurobehavioral effects, including effects on neural sensitization, motor-related behaviors, and learning and memory.

###### Neural Sensitization

- Consistency and Study Confidence: One medium confidence and five low confidence studies reported effects in rats and mice; however, the possible influence of indirect effects from altered olfaction, irritation, or stress responses specific to the animal exposure scenarios cannot be ruled out.
- Strength and Precision: Effects persisted weeks after exposure in several studies.
- Dose-Response: Some studies reported increased effects with increasing exposure duration.
- Biological Plausibility: Although no MOA was identified, several well-conducted studies show molecular and neurochemical changes in the brain, and changes to circulating stress hormones, at formaldehyde levels lower than those causing sensitization, providing some plausibility for the observed apical effects.

###### Motor-related Behaviors

- Consistency and Study Confidence: Eight low confidence studies in rats and mice were consistent in showing some change in motor-related behaviors; however, all studies had exposure deficiencies or were complicated by potential irritation-related confounding and one medium confidence study did not observe effects.
- Strength and Precision: Effects persisted weeks after exposure in one study.
- Dose-Response: Most responses were dose-dependent.
- Biological Plausibility: Although no MOA was identified, several well-conducted studies show molecular and neurochemical changes in the brain at formaldehyde levels lower than those affecting these behaviors, providing some plausibility for the observed apical effects.

###### Learning and Memory

- Consistency and Study Confidence: Effects were consistently observed across five low confidence studies in rats and mice; however, all studies had exposure deficiencies, and most did not evaluate effects on motor activity as a potential contributing factor.
- Strength and Precision: Effects persisted weeks after exposure in one study.
- Dose-Response: Responses were dose-dependent in two studies.
- Biological Plausibility: Although no MOA was identified, several well-conducted studies show molecular and neurochemical changes in the brain at formaldehyde levels lower than those affecting these behaviors, providing some plausibility for the observed apical effects.

###### Nervous System Disease

No informative animal studies related to nervous system disease were identified (indeterminate animal evidence).

###### Developmental Neurotoxicity

The following factors were influential to the synthesis judgment that the animal neuropathology studies provide slight evidence of formaldehyde exposure-induced developmental neurotoxicity.

- Consistency and Study Confidence: One medium confidence study (in two publications) and one low confidence study reported developmental neuropathology. Certainty is reduced as all studies were conducted in the same laboratory and only at high formaldehyde levels (>7 mg/m^3^). Small sample size and risk of bias from potential litter effects increase uncertainty.
- Strength and Precision: Toxicity persisted well after exposure, suggesting severe effects.
- Dose-Response: Magnitude generally increased with formaldehyde exposure level.
- Biological Plausibility: Although no MOA was identified, several well-conducted studies show molecular and neurochemical changes in relevant brain regions, providing some plausibility for the observed apical effects.

#### Evidence on Mode of Action

Little mode of action (MOA) information regarding potential nervous system effects following formaldehyde inhalation is available. To date, there are no definitive data supporting a specific mechanism for effects on nervous system structure or function. As appreciable amounts of formaldehyde are not expected to reach the systemic circulation or CNS to elicit direct effects, any potential mechanisms would need to be indirect. Thus, this section focuses on mechanisms that might secondarily result from alterations to the respiratory system (see Appendix C.7). As such, only data from formaldehyde inhalation studies are discussed, and confidence in the findings based on individual study evaluations is emphasized (see Appendix B.3.7). Although none has been confirmed experimentally, several biologically plausible, but speculative sequences of mechanistic changes that might support indirect effects can be hypothesized based on the available formaldehyde-specific data, including:

1) Repeated activation of sensory nerves (e.g., trigeminal, vagal) causing sensitization or neurogenic inflammation leading secondarily to effects on neuronal populations unrelated to pain and irritation pathways—based primarily on three medium (Kulle and Cooper, 1975; Fujimaki et al., 2004b; Ahmed et al., 2007) and one low confidence (Tsukahara et al., 2006) studies.

Repeated stimulation of sensory nerve fibers relaying information related to formaldehyde exposure to neuronal nuclei might eventually lead, indirectly, to lasting changes in centrally located neurons or soluble factors; however, specific data assessing this possibility, and the downstream consequences of such potential changes, remain unexamined. Formaldehyde inhalation has been shown to increase the electrical activity of trigeminal nasal afferents at concentrations below 1 mg/m^3^ (Kulle and Cooper, 1975), which appears to cause neurogenic inflammation, a process whereby stimulation of sensory nerve endings causes localized (e.g., into airway tissue) release of neuropeptides (e.g., the tachykinin, substance P) that elicit local inflammatory responses (see discussion in Section 3.2.1). In addition to the “axon reflex” that can be induced upon sensory nerve stimulation (causing a localized release of factors), if the stimulus is of sufficient intensity or duration, signaling along ascending pathways from these afferents can continue, and eventually might lead to central sensitization where the excitability or responsiveness of afferent nerve fibers is enhanced (Woolf and Salter, 2000).

While changes in neuronal nuclei associated with ascending pathways related to pain and irritation signals seems likely following formaldehyde inhalation, there are no data or hypotheses available to inform how this might indirectly affect other neuronal nuclei. Regardless of the unexplainable connection between sensory nerve stimulation and changes in presumably unrelated neuronal nuclei, hippocampal neurochemical changes which appear to be related to neurogenic inflammation, were observed in the absence of neuronal injury in a series of subchronic formaldehyde inhalation studies by Fujimaki and colleagues at formaldehyde levels as low as 0.1 mg/m^3^ (Tsukahara et al., 2006; Fujimaki et al., 2004a; Ahmed et al., 2007). Importantly, these effects were generally only observed after stimulation with foreign materials known to cause an allergic response. Although the evidence related to potential neurogenic inflammation has been primarily observed in the airways, some factors released as a result of this process can be long-lived, and receptors for these upregulated cytokines and neuropeptides, including substance P, are prevalent throughout the CNS (Douglas et al., 2008). These data suggest the possibility that sensory nerve stimulation of sufficient duration and intensity, perhaps particularly in allergic individuals, might eventually result in lasting changes in CNS regions that regulate behaviors unrelated to pain or irritation responses. However, dose-response relationships for the observed mechanistic changes were unclear and data are not available to inform some of the essential logical connections that would be necessary to connect peripheral stimulation to these central changes. An additional uncertainty with this hypothesized relationship is a lack of understanding whether and to what extend this potential mechanism might be involved following chronic exposure. For example, although another respiratory irritant, capsaicin, also causes neurogenic inflammation, no neurogenic inflammatory response to subsequent stimuli is observed following long-term exposure to capsaicin because tachykinins become depleted from sensory neurons (Kashiba et al., 1997; Cadieux et al., 1986). Further, no data are available to inform human relevance, and some suggest responses might differ across species (e.g., distribution of substance P receptors in the brain can differ across species (Rigby et al., 2005)).

2) Neuronal activation following stimulation of the olfactory epithelium leading, indirectly, to alterations in neuronal targets unrelated to olfaction or, directly, to alterations in olfactory-dependent behaviors—based primarily on two medium (Hayashi et al., 2004; Boja et al., 1985) and one low confidence (Zhang et al., 2014) study.

Formaldehyde is not only a chemical irritant, but also an odorant, and its odor is typically detectable at lower levels than those causing irritation. Repeated and prolonged stimulation of neuronal olfactory receptors in the nasal epithelium at posterior regions of the upper respiratory tract (URT) might affect neurons along ascending pathways related to olfaction; however, similar to the hypothesis presented above, no data exist to describe how such changes could indirectly affect neurons or neuronal regions unassociated with olfaction. Hayashi et al. (2004) reported that subchronic, but not acute, formaldehyde exposure increases the activity of periglomerular (PG) cells in the main olfactory bulb (OB). Increases in the number of tyrosine hydroxylase (TH)^+^ PG cells were observed at ≥0.1mg/m^3^, with no differences in PG cell number or size of the OB (indicating increased TH synthesis in TH^−^ PG cells rather than new cell formation). These changes might be related to observed decreases in the synapse protein, SNAP25, in the OB after periodic exposure (twice daily 30-minute exposures for 14 days) to high levels of formaldehyde (Zhang et al., 2014), although these latter results are interpreted with low confidence. The results in Hayashi et al. (2004) appear to highlight sensory-induced adaptive properties of the OB in relation to dopaminergic function (TH is an essential enzyme for dopamine synthesis). OB dopamine affects odor detection and can affect odor-related behaviors (e.g., impaired learning was observed with increased dopamine D2 receptor signaling by Escanilla et al. (2009)). Thus, it is considered plausible that formaldehyde exposure could modify rodent behaviors with an olfactory component (e.g., motor-related behaviors; learning and memory in land maze tests); however, the potential for human behaviors, which are far less reliant on odorant signals, to be significantly impacted is unlikely.

It is unknown whether the adaptive changes observed in OB neurons result in alterations in neural circuitry. To date, no electrophysiological experiments have been conducted to specifically address the potential for an association between formaldehyde exposure and CNS electrophysiological changes. From the OB, olfactory signals are typically conveyed to higher order neurons, including those in the amygdala, hypothalamus, and olfactory areas of the entorhinal and piriform cortex. Possibly in relation to this, there is some suggestion of altered dopaminergic or serotonergic signaling in the hypothalamus with high-level formaldehyde exposures [6.15 mg/m^3^; (Boja et al., 1985)], but these changes (increased dopamine and 5-HIAA, a serotonin metabolite) were only evaluated acutely following exposure, have not been linked to behavioral changes, and contrast somewhat with suggestive observations of decreases in TH-positive cells across several brain regions at lower levels (Li et al., 2016). In addition, it remains speculative to infer that changes in olfaction-related ascending pathways after formaldehyde exposure might modify neural cell populations that are likely to be unrelated to those specific olfactory neuronal circuits. Overall, the cascade of events surrounding these adaptive changes remains unknown.

3) Altered hypothalamus-pituitary-adrenal gland (HPA) axis signaling (possibly linked to events above) causing persistent, stress-induced changes in behaviors—based primarily on two medium confidence studies (Sorg et al., 2001a; Sari et al., 2004).

Stress can be a strong modifier of behavior, particularly at early lifestages. (Sorg et al., 1996; Sorg et al., 2001a) have suggested that behavioral sensitization to formaldehyde may be linked to alterations in HPA axis control of corticosterone or sensitization of limbic circuitry following repeated exposure. In support of this hypothesis, elevated numbers of corticotropin-releasing hormone (CRH)^+^ neurons in the hypothalamus (at 0.49 mg/m^3^) and adrenocorticotropic hormone (ACTH)^+^ cells in the pituitary gland (at 0.1 mg/m^3^) were observed after subchronic formaldehyde exposure (Sari et al., 2004), while increased serum corticosterone (at 0.86 mg/m^3^) was evident after exposure for only 4 weeks (Sorg et al., 2001a). These findings may be related to evidence suggesting depressed hippocampal glucocorticoid responses at 2.46 mg/m^3^ from a single short-term (7 day), low confidence study (Li et al., 2016). CRH and ACTH represent precursor steps in the release of glucocorticoids into the circulation following HPA axis stimulation, and corticosterone is the rodent glucocorticoid equivalent of cortisol in humans. Reported disruptions in sleep behavior [observed at 2.46 mg/m^3^ formaldehyde by (Sorg et al., 2001b)] may also be linked to HPA axis dysfunction (Buckley and Schatzberg, 2005). In addition to highlighting the potential for formaldehyde-induced effects on allergy-related responses to impact the HPA axis, Sari et al. (2004) hypothesized that these stress-related responses might have resulted from neural sensitization via amplification of CNS circuits with repeated exposure; however, as previously mentioned, no well-conducted formaldehyde inhalation studies assessing electrophysiological endpoints were identified. Although formaldehyde exposure appears to be correlated with HPA axis-associated changes, no studies describe exactly how these CNS-regulated HPA responses could be modified by formaldehyde, highlighting a critical information gap. Importantly, the available studies are unable to rule out the possibility that the stress responses might be caused by the animal exposure-specific phenomenon of “inescapable stress” highlighted in Sorg et al. (1996). The available studies have not fully examined the temporal profile of these changes (acute stress responses are not necessarily adverse), and no studies have demonstrated that formaldehyde-induced stress leads to persistent neurobehavioral changes, functional alterations (e.g., through impaired neurogenesis), or neuroanatomical changes.

4) Changes in neuronal health and function due to indirect CNS oxidative stress or excitatory changes (possibly linked to events described above)—based primarily on two medium (Songur et al., 2008; Ahmed et al., 2007) and three low confidence (Songur et al., 2003; Mei et al., 2016; LICM, 2008) studies.

Markers of oxidative stress in the CNS are commonly associated with altered neuronal health and behavior. Songur et al. (2008) hypothesized that formaldehyde exposure may cause persistent brain changes via oxidative damage. Although a linkage between altered redox balance and hippocampal neuropathology was not tested in the stereological studies from this laboratory (Sarsilmaz et al., 2007; Aslan et al., 2006), an earlier study (Songur et al., 2003) observed reversible upregulation of hippocampal heat shock protein 70, an oxidative stress-responsive protein. Several other studies using molecular endpoints also support that formaldehyde inhalation may disrupt brain oxidative stress responses (i.e., increased malondialdehyde and nitric oxide levels; decreased superoxide dismutase activity and glutathione levels), particularly in the cerebellum, following high-level formaldehyde exposures in juvenile rats [at 7.36−14.7 mg/m^3^ in (Songur et al., 2008)] and adult mice [at ~3 mg/m^3^ in Mei et al. (2016)]. Songur et al. (2008) observed effects that persisted up to 60 days post-exposure. Lower-level exposures (e.g., 0.123 mg/m^3^) for up to 24 hours did not cause changes in brain 8-OHdG to dG ratios (Matsuoka et al., 2010). The evidence for oxidative stress in the brain could be related to prolonged increases in inflammatory mediators in the blood after formaldehyde exposure, including reactive oxygen species, hormones, or other factors (see Appendix C.7); however, this potential linkage has not been tested. Relatedly, changes in oxidative stress markers might reflect effects on excitatory neurotransmission. Specifically, acute formaldehyde inhalation has been shown to increase expression of NMDA receptor subunits (e.g., NR2B) in nasal tissue (Hester et al., 2003) and forebrain regions (LICM, 2008), while subchronic exposure in rats sensitized to allergen increased NMDA receptor expression (Ahmed et al., 2007) but not protein levels (Tsukahara et al., 2006). However, the cause(s) and functional consequences of these reported molecular increases have not been examined. In general, an explanation for oxidative stress-related changes in the absence of systemic distribution of formaldehyde or very high formaldehyde exposure levels is unavailable, limiting the feasibility of this potential mechanism.

Overall, no MOA for potential formaldehyde-induced nervous system effects is available.

##### Summary of Inferences Regarding Mode of Action

No verified MOA exists for how formaldehyde could elicit CNS effects without systemic distribution; however, several lines of evidence exist to support the potential for indirect effects on the CNS.

#### Evidence Integration Summary

Numerous human and animal studies were available and, although multiple lines of evidence suggest that some concern for nervous system effects following formaldehyde inhalation is warranted, major deficiencies in study conduct were identified and the database is considered incomplete. No experimentally supported MOA is available to explain how formaldehyde inhalation could cause nervous system effects, although some potentially relevant mechanistic changes in the brain have been observed in well-conducted studies. Summary evaluations of the evidence for potential nervous system effects of formaldehyde inhalation exposure are provided in Table 3-50.

In human studies, evidence of an association between formaldehyde exposure and ALS was suggested across four studies in different populations by two separate groups of researchers. Positive associations observed in a large prospective study were somewhat corroborated by a few (but not most) comparisons in the other studies, noting that some associations were based on a very small number of cases or secondary analyses. However, three of the studies had uncertainties in the assignment of individual exposure to formaldehyde and two of the four did not observe a dose-response relationship when the data were stratified by estimated formaldehyde levels. In addition, the results were not corroborated in another study in a different population, which had greater certainty in individual exposure assessments. Based on these uncertainties, the currently available human evidence is interpreted as slight. Importantly, however, the unexpected nature of the observed associations between formaldehyde exposure and this rare and fatal disease across a growing number of studies (the first association was reported in 2009, with some corroborating evidence in 2015 and 2016) identifies an urgent need for additional research. As no experimental animal or mechanistic studies specific to this effect were identified (i.e., indeterminate), overall, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause the fatal human disease, ALS, but additional study is needed for a stronger judgment. This is primarily based on epidemiological studies in occupational settings (presumably higher levels of exposure); however, there were notable uncertainties in the studies’ exposure assessments.

Although numerous studies reported changes in behavior following formaldehyde exposure, the evidence was not considered adequate to support a causal hazard conclusion, as it was primarily based on rodent studies with notable methodological limitations, with more limited supporting data from studies in humans. Effects in learning and memory tests, and performance in tests of motor-related behaviors, were relatively consistent across the available animal data, and several human studies reported coherent, but more marginal, changes in related tests. However, the available experiments had significant methodological deficiencies and, overall, the data were not attributable to formaldehyde alone. Based on the methodological limitations of the available studies, both the human and animal evidence for effects in learning and memory tests, and on motor-related behaviors, is considered slight. Although no established MOA exists for changes in these behaviors, several well-conducted studies reporting molecular and structural effects in relevant brain regions (e.g., limbic structures and cerebellum) provide some biological plausibility for these effects. Taken together, it was judged that the evidence suggests, but is not sufficient to infer, that formaldehyde exposure might cause these potential behavioral effects.

Somewhat separate from the other reported behavioral effects, formaldehyde inhalation in rodents was also reported to be associated with sensitization-related changes in behavior. While several animal studies of varying quality observed amplified behavioral responses after formaldehyde exposure, interpretation of the results is unclear. Additional data are needed to rule out any potential influence from factors other than formaldehyde exposure. No human studies were available to inform this endpoint (i.e., indeterminate). In addition, although some biological plausibility is provided by neurochemical and hormonal changes that may be consistent with such effects, without mechanistic information to verify that formaldehyde exposure alone resulted in these effects (e.g., supporting a reasonable MOA or ruling out alternative explanations), the animal findings are considered slight. As uncertainties also exist regarding the relevance of these tests to human exposure scenarios, based on the data overall, it was judged that the evidence suggests that formaldehyde might cause neural sensitization-related behavioral changes.

Thus, based on the available database of studies, it was concluded that the available evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause behavioral effects. The primary support for this conclusion is from low confidence studies in experimental animals, many of which reported effects at ≤1 mg/m^3^. Given that this judgment relates to multiple manifestations of potential behavioral toxicity (i.e., learning and memory; motor- or anxiety-related activity; and neural sensitization), with some findings reported at low-exposure levels, this represents a significant data gap.

Data from experimental animal studies also suggest that excessive formaldehyde inhalation (levels >7 mg/m^3^) may cause developmental neurotoxicity. The evidence most informative to this potential health effect was a medium confidence study (i.e., two publications on the same experiment) examining neuropathological changes in rats; a few low confidence studies reporting somewhat equivocal evidence for developmental effects other than neuropathology did not contribute. While the methods used in this study to evaluate developmental neuropathology were sensitive and designed to minimize bias, and the endpoint (persistently decreased neuron number) is adverse, relevant to humans, and without contradictory data, there were notable uncertainties introduced by the study design that warrant replication of the results. These include a very small sample size (n = 3 litters), as well as lack of control for potential litter effects. As some mechanistic changes in the hippocampus and related brain regions after developmental exposure have been reported in well-conducted studies, indirect effects of formaldehyde exposure on the CNS have some demonstrated plausibility. In the absence of confirmatory studies (e.g., in other species; by other laboratories; using more informative study designs), the evidence for effects in animals is considered slight. No studies in humans were available to inform developmental neurotoxicity (i.e., indeterminate). Overall, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause effects on the developing nervous system, primarily based on a set of neuropathology studies from the same laboratory. The primary support for this judgment is from animal studies of neuropathology following developmental exposure to >7 mg/m^3^ of formaldehyde. Given the potential for children to be exposed to formaldehyde, this area represents a research need.

Overall, conclusive evidence of a nervous system health hazard in humans exposed to formaldehyde was not identified. Given that, across a number of studies, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple nervous system health effects in humans given sufficient exposure conditions^33^ (see Table 3-50), and the general lack of comprehensive and rigorous experiments across the database, additional study is warranted.

Table 3-50 Evidence integration summary for effects of formaldehyde inhalation on nervous system disease, specifically amyotrophic lateral sclerosis

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Nervous System Disease: Amyotrophic Lateral Sclerosis
Human | Consistency and Study Confidence | - Strong effects in one medium confidence study, with more limited support from three other medium confidence studies (two studies from the same researchers).; - Effects were from large, wellconducted longitudinal or retrospective studies. | - No association in one medium confidence study.; - Uncertainty in individual exposure assessments and effect estimates based on a very small number of exposed cases. | Slight; Some mixed but strong evidence for effects from a few occupational studies, but no dose- or duration-dependence was observed, plausibility for this effect is lacking, and important aspects of the studies’ design introduce significant uncertainty. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause increases in ALS incidence or mortality, given sufficient exposure conditions.^a^; Primarily based on slight human evidence from occupational studies (presumably higher levels of exposure than in residential scenarios), generally with uncertain exposure assessments.; Potential susceptibility: ALS disproportionately affects males, the focus of most of the available formaldehyde studies.; (Note: Confirmatory effects in a medium confidence human study with a reasonable number of exposed cases and more certain measures of exposure would be expected to adjust this to evidence indicates [likely]).
Human | Strength and Precision | - Large and precise association in one study.
Human | Dose-Response | | - Lack of exposure-response trends in studies with adequate data to examine the potential for such trends.; - Inconsistency in associations with duration.
Human | Coherence | N/A, no biologically related outcomes were identified
Human | Biological Plausibility | | - No MOA or relevant mechanistic studies in humans were identified, and this effect is surprising (i.e., plausibility is lacking) without systemic distribution.
Animal | No available animal studies address this outcome. | | | Indeterminate No studies.
Other inferences | - Relevance to humans: The effect was observed in humans.; - MOA: No verified MOA exists for how formaldehyde could elicit effects in motor neuron-related systems without systemic distribution. Additional study into the potential involvement of systemic oxidative stress (see also Appendix C.7) is warranted, given research interest in associations between elevated oxidative stress and ALS progression.

Abbreviations: ALS = amyotrophic lateral sclerosis; MOA = mode of action; CNS = central nervous system. N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define what might be the “sufficient exposure conditions” for developing this outcome.

Table 3-51 Evidence integration summary for effects of formaldehyde inhalation on developmental neurotoxicity

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Developmental Neurotoxicity
Human | No available human studies address this outcome | | | Indeterminate No studies | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause developmental neurotoxicity, given sufficient exposure conditions.^a^; Based primarily on slight animal evidence from one laboratory that exposed postnatal rats to >7 mg/m^3^ formaldehyde.; Potential susceptibility: The available data relate to postnatal exposure (other untested lifestages might exhibit even greater sensitivity).; (Note: confirmatory effects in a medium confidence animal study from another laboratory or in another species, particularly one testing lower exposure levels, would be expected to adjust this to evidence indicates [likely].)
Animal | Consistency and Study Confidence | - Effects in one medium confidence study (reported in two papers) and one low confidence study of the male rat hippocampus (less convincing evidence on other endpoints from other low confidence studies did not contribute).; - No conflicting evidence (i.e., no comparable evaluations).; - The outcome methods used minimize bias. | - The studies were conducted by a single laboratory,; - Low sample size and analyses on a pup (not litter) basis complicate the interpretation of the results without independent replication.; - Only tested formaldehyde levels >7 mg/m^3^ (which complicates interpretation of human relevance). | Slight; Concerning findings from a single study with methodological limitations that complicate interpretation
Animal | Strength and Precision | - Multiple indications of toxicity persisted 60 days after exposure, suggesting the effect may be pronounced or permanent. | | Slight; Concerning findings from a single study with methodological limitations that complicate interpretation
Animal | Dose-Response | - Studies were not well-designed to inform dose-response patterns, but magnitude generally increased with exposure. | | Slight; Concerning findings from a single study with methodological limitations that complicate interpretation
Animal | Coherence | N/A, narrow scope of evaluated outcome | | Slight; Concerning findings from a single study with methodological limitations that complicate interpretation
Animal | Biological Plausibility | - Several animal studies with wellconducted exposures (including developmental exposure) demonstrate molecular and neurochemical changes in relevant (i.e., limbic) brain regions at formaldehyde levels lower than those causing pathology, providing plausibility. | | Slight; Concerning findings from a single study with methodological limitations that complicate interpretation
Other inferences | - Relevance to humans: Uncertainty regarding the relevance of the animal evidence exists, as the studies only tested high levels of formaldehyde expected to cause strong irritant effects that may not occur in humans; otherwise, rodent neuropathology is relevant to humans and is adverse.; - MOA: No verified MOA exists for how formaldehyde could elicit CNS effects without systemic distribution, although evidence related to several indirect mechanisms of potential relevance was identified.

Abbreviations: MOA = mode of action; CNS = central nervous system. N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define what might be the “sufficient exposure conditions” for developing this outcome.

Table 3-52 Evidence integration summary for effects of formaldehyde inhalation on neurobehavior

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Neural Sensitization | | | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple manifestations of potential behavioral toxicity, given sufficient exposure conditions.^a^; Primarily based on a number of low confidence studies in rats and mice, many of which observed effects after formaldehyde exposure ≤1 mg/m^3^.; (Notes: Confirmatory effects supporting neural sensitization in one medium confidence study from another laboratory alongside mechanistic confirmation of the human relevance and adversity of the animal findings would be expected to adjust this to evidence indicates [likely]; as the data for other types of behavioral effects are only based on low confidence studies, it is expected that confirmatory effects of behavioral changes other than neural sensitization in multiple medium confidence studies would be needed to adjust this to evidence indicates [likely].); Potential susceptibility: Unknown, as well-conducted developmental studies of these effects were not identified.
Human evidence | No available human studies address this outcome. | | | Indeterminate No studies
Animal evidence | Consistency and Study Confidence | - Consistent effects in one medium confidence and five low confidence studies across two species (rats and mice).; - No contrary results. | - Behaviors may be complicated by possible olfaction, irritation, and stress responses specific to animal exposure scenarios that were untested.; - Primarily low confidence studies. | Slight; Effects were observed in several, primarily low confidence, studies; however, nonspecific contributors to the responses cannot be reasonably ruled out.
Animal evidence | Strength and Precision | - Some studies show that responses persist weeks after exposure, suggesting the effect might be pronounced. | | Slight; Effects were observed in several, primarily low confidence, studies; however, nonspecific contributors to the responses cannot be reasonably ruled out.
Animal evidence | Dose-Response | - Some studies show that responses increase with increasing exposure duration. | | Slight; Effects were observed in several, primarily low confidence, studies; however, nonspecific contributors to the responses cannot be reasonably ruled out.
Animal evidence | Coherence | N/A | | Slight; Effects were observed in several, primarily low confidence, studies; however, nonspecific contributors to the responses cannot be reasonably ruled out.
Animal evidence | Biological Plausibility | - Several studies with well-conducted exposures demonstrate molecular and neurochemical changes in the brain, and changes to circulating stress hormones, at formaldehyde levels comparable or lower than the levels causing sensitization; this provides support for plausibility. | | Slight; Effects were observed in several, primarily low confidence, studies; however, nonspecific contributors to the responses cannot be reasonably ruled out.
Other inferences | - Relevance to humans: Translatability to human exposure scenarios and adversity in humans remains unclear, requiring further study.; - MOA: No verified mechanism exists for how formaldehyde could elicit CNS effects without systemic distribution; however, several lines of evidence exist to support the potential for indirect effects on the CNS.
Tests of Motor-related Behaviors
Human evidence | Consistency and Study Confidence | - Effects in two low confidence studies and weak (near equivocal) effects in one medium confidence study.; - Effects were observed across demographics and behavioral tests. | - Likely co-exposures were not wellevaluated, and data are primarily based on acute exposure.; - No effect in one low confidence study. | Slight
Human evidence | Strength and Precision | N/A | | Slight
Human evidence | Dose-Response | | - Lack of dose-dependence. | Slight
Human evidence | Coherence | N/A | | Slight
Human evidence | Biological Plausibility | No relevant human studies identified | | Slight
Animal evidence | Consistency and Study Confidence | - Effects in eight low confidence studies across laboratories in both sexes of rats and mice (multiple strains). | - No effect in one medium confidence study; - All studies observing effects had test article deficiencies and/or were complicated by irritation-related responses, and few tests assessed a discrete function (e.g., motor activity). | Slight
Animal evidence | Strength and Precision | - One study reported effects persisting for weeks, suggesting a pronounced effect. | | Slight
Animal evidence | Dose-Response | - Most responses were dose-dependent. | | Slight
Animal evidence | Coherence | N/A | | Slight
Animal evidence | Biological Plausibility | - Several studies with well-conducted exposures demonstrate molecular and neurochemical changes in the brain at formaldehyde levels comparable or lower than the levels causing the apical effects; this provides some support for plausibility. | | Slight
Other inferences | - Relevance to humans: The commonly used tests and the changes observed at levels not expected to induce irritation are considered relevant to humans and potentially are adverse.; - MOA: No verified mechanism exists for how formaldehyde could elicit CNS effects without systemic distribution; however, several lines of evidence exist to support the potential for indirect effects on the CNS.; - Other: The duration- and timing-dependence of these potential effects is unknown, as most data are from acute and shortterm exposure of formaldehyde levels >7 mg/m^3^ (high levels which further complicate interpretation).
Tests of Learning or Memory
Human evidence | Consistency and Study Confidence | - Effects in three low confidence, independent studies. | - All were low confidence studies that had significant coexposures or poorly comparable groups; - No effect in one low confidence study. | Slight
Human evidence | Strength and Precision | N/A | | Slight
Human evidence | Dose-Response | - Effects were related to duration of exposure across studies. | - No dose-dependent effects were observed with controlled exposure. | Slight
Human evidence | Coherence | N/A | | Slight
Human evidence | Biological Plausibility | No relevant human studies identified | | Slight
Animal evidence | Consistency and Study Confidence | - Effects in five low confidence studies from multiple research laboratories across various durations of exposure and in both sexes of rats and mice; - No contrary results. | - All were low confidence studies that had test article deficiencies, and most did not evaluate motor activity as a contributing factor. | Slight
Animal evidence | Strength and Precision | - Effect magnitude increased with repeated exposure and effects persisted weeks after exposure (in one subchronic study). | | Slight
Animal evidence | Dose-Response | - Effects were dose-dependent in two studies. | | Slight
Animal evidence | Coherence | N/A | | Slight
Animal evidence | Biological Plausibility | - Several studies with well-conducted exposures demonstrate molecular and neurochemical changes in the brain at formaldehyde levels comparable or lower than the levels causing the apical effects; this provides some support for plausibility. | | Slight
Other inferences | - Relevance to humans: The commonly used tests and the changes observed at levels not expected to induce irritation are considered relevant to humans and potentially are adverse.; - MOA: No verified mechanism exists for how formaldehyde could elicit CNS effects without systemic distribution; however, several lines of evidence exist to support the potential for indirect effects on the CNS.; - Other: The duration- and timing-dependence of these potential effects is unknown, as most data are from acute and shortterm exposure of formaldehyde levels >7 mg/m^3^ (high levels which further complicate interpretation).

Abbreviations: MOA = mode of action; CNS = central nervous system. N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define what might be the “sufficient exposure conditions” for developing this outcome. (i.e., neural sensitization, tests of motor-related behaviors, and tests of learning and memory), either individually or as encompassed by the broader category of neurobehavioral tests.

### 3.3.2 Developmental and Reproductive Toxicity

Studies in humans, and a number of animal studies have reported effects of inhaled formaldehyde on pre- and postnatal development and on the female and male reproductive systems. Three studies evaluated residential exposure during pregnancy and fetal and infant growth measures, including ultrasonographic biometric measures, birth weight and head circumference, and postnatal growth. The most common outcome reported by occupational epidemiology studies was an elevated spontaneous abortion risk in different industries, with strong associations seen in the highest exposure categories. Further, maternal, and paternal formaldehyde exposure was associated with decreased fecundity,^34^ indicated by a longer time to achieve a pregnancy, in two studies of employees in the woodworking industry (out of a total set of three studies). The associations among female workers may reflect either toxicity to the reproductive system of the mother (ability to achieve and support the pregnancy) or the developing fetus. Together, the findings among women provide moderate evidence of developmental or female reproductive toxicity. In animal studies, there is indeterminate evidence for manifestations of developmental toxicity (i.e., decreased survival, decreased growth, or increased evidence of structural anomalies) or female reproductive toxicity (ovarian and uterine pathology, ovarian weight, and hormonal changes). All available studies were of low confidence, primarily due to exposure-quality concerns (i.e., the use of formalin, or an uncharacterized test substance).

Two studies of exposure to male workers from one research group provide slight evidence that formaldehyde exposure is associated with lower total and progressive sperm motility, and delayed fertility and spontaneous abortion. The epidemiological observations are supported by robust evidence from experimental studies in animals that used paraformaldehyde to expose the animals. Across this set of studies, coherent evidence for a range of effects on the male reproductive system was demonstrated, including quantitative histopathological effects in the testes and epididymides, decreased serum testosterone (T), decreased sperm count and motility, and increased sperm morphological abnormalities. However, limitations in the animal study database for male reproductive toxicity include a general lack of functional measures in the available studies and no studies that tested formaldehyde levels below 6 mg/m^3^, warranting additional study.

Overall, the evidence indicates that inhalation of formaldehyde likely causes increased risk of developmental or female reproductive toxicity in humans, given sufficient exposure conditions. This conclusion is based on moderate evidence in observational studies finding increases in time-to-pregnancy (TTP) and spontaneous abortion risk among women with occupational formaldehyde exposures. The evidence in animals is indeterminate, and a plausible, experimentally verified MOA explaining such effects without systemic distribution of formaldehyde is lacking. Likewise, the evidence indicates that inhalation of formaldehyde likely causes increased risk of reproductive toxicity in men, given sufficient exposure conditions, based on robust evidence in animals that presents a coherent array of adverse effects in two species testing formaldehyde concentrations >6 mg/g^3^, and slight evidence from observational studies of occupational exposure, and no plausible, experimentally verified MOA explaining such effects without systemic distribution of formaldehyde. However, some support for indirect effects in rodents is provided by relevant mechanistic changes in male reproductive organs.

#### Human Studies

The observational studies of reproductive toxicity or pregnancy outcomes evaluated associations with exposure during pregnancy in three studies and with occupational exposure among cosmetologists, woodworkers, laboratory workers, and hospital staff. The evidence regarding TTP, spontaneous abortion, pre- and post-natal growth and other birth outcomes, and male reproductive toxicity was synthesized, and the studies summarized in Tables 3-53 through 3-56, ordered by the level of confidence in the study result (i.e., high, medium, or low) and then by publication date. Six of the studies that met the PECO criteria were considered not informative after evaluation (Stücker et al., 1993; Shumilina, 1975; Seitz and Baron, 1990; Saurel-Cubizolles et al., 1994; Ericson et al., 1984; Axelsson et al., 1984). The study evaluations are included in Appendix B.3.8.

##### Female Reproductive or Developmental Toxicity

###### Time to pregnancy and subfertility

TTP is a measure of fertility and has been characterized in terms of number of menstrual cycles that occurred prior to conception. TTP of greater than 12 months of unprotected intercourse is indicative of infertility ((Wilcox, 2010), p. 123). Increased TTP might result from potential effects on gametogenesis, transport, fertilization, migration, implantation, or survival of the embryo (Baird et al., 1986). Thus, the measure reflects a potential impact on multiple biological processes, possibly in both partners, and can be sensitive to the detection of events early during pregnancy that usually cannot be easily detected in population-based studies. Because it is evaluated in number of months or menstrual cycles, TTP is informative regarding exposures with impacts over shorter time periods (e.g., <1 year). TTP is not a measure of infertility as these studies only include women who became pregnant and had a live birth.

One medium confidence study (Taskinen et al., 1999) and one low confidence study (Zhu et al., 2005) were identified that evaluated effects on TTP in relation to maternal exposure to formaldehyde (see Table 3-53). TTP was retrospectively ascertained using self-completed questionnaires (Taskinen et al., 1999). Taskinen et al. (1999) used an appropriate analytical approach, involving the comparison of fecundability^35^ among four exposure groups. The association of maternal formaldehyde exposure with TTP became significantly increased in the highest exposure group with an 8-hour TWA (TWA8) exposure of 0.27 mg/m^3^. The fecundability density ratio (FDR) for individuals in the highest formaldehyde exposure category compared to nonexposed individuals, adjusting for potential confounders and phenol exposure was 0.57 (95% CI 0.37, 0.85). The FDRs for organic solvents, dusts, wood dusts, and phenols in models that adjusted for potential confounders, including formaldehyde as a coexposure, were all greater than 0.90 (p > 0.05). Therefore, the observed association with formaldehyde was not explained by these other exposures because they were not associated with longer TTP. FDR was lowest among 17 women who did not wear gloves, out of 39 women in the highly exposed group (FDR = 0.51; 95% CI 0.28, 0.92), suggesting that dermal exposure contributed to increased risk of increased TTP. In addition to the detailed exposure assignments, (Taskinen et al., 1999) reduced the potential for selection bias by recruiting from female members of a wood workers union who had been employed at least six months prior to their pregnancy. Thus, selection into the study was not conditional on being currently employed in the industry at the time of the study. Zhu et al. (2005) did not observe an association with reduced TTP in a study of lab technicians that assigned exposures based on broad task categories.

Table 3-53 Epidemiology studies describing effects on time to pregnancy in relation to maternal formaldehyde exposure

Study and design | Results
Reference: Taskinen et al. (1999); Retrospective cohort study, Finland; Population: Women (n = 3,772), recruited from a woodworkers’ union and other businesses involving wood processing, 1,094 women eligible (born between 1946 and 1975, had a live birth at age 20–40 years during 1985–1995, had worked in the wood processing industry for at least 1 month, and had first employment in the wood processing industry beginning at least 6 months before the index pregnancy). The first eligible pregnancy was the index pregnancy. Information about personal characteristics, pregnancies, and exposures was collected from mailed questionnaires; response rate 64%. After other exclusions (primarily infertility history, unknown TTP, and contraceptive failure), the final sample included 602 women. Period of recall of TTP period: 1–11 years.; Exposure: Questionnaire on exposure to specific agents including hours/week during TTP period. Mean daily exposure to formaldehyde was based on measurements taken at the factories where the women worked during the early 1990s or, if measurements unavailable, from comparable industries. Sampling protocol was not described. Formaldehyde concentrations were obtained from comparable industries for 46, 31, and 61% of women in low, medium, and high exposure categories, respectively.; Formaldehyde concentration in factories by exposure category:; Low mean 0.07 ppm (0.086 mg/m^3^)^*^, range 0.01 to 0.3 ppm (0.012 to 0.37 mg/m^3^);; Medium mean 0.14 ppm (0.17 mg/m^3^), range 0.05 to 0.4 ppm (0.062 to 0.49 mg/m^3^);; High mean 0.33 ppm (0.41 mg/m^3^), range 0.15 to 1.0 ppm (0.18 to 1.2 mg/m^3^) Other chemicals with measurements: phenol, organic solvents, wood dust, other dusts.; Methods: Analysis: discrete proportional hazards regression; outcome, FDR, ratio of average incidence density of pregnancies in exposed compared to employed, unexposed women); for covariates in model, see results; significance assessed by likelihood ratio test.; Evaluation: ^a^; Medium confidence; Expect some error in individual exposure assignments. | TTP by formaldehyde category
| | | N | FDR^a^ | 95% CI
| Not Exposed | | 367 | 1.00 | −
| Low | | 119 | 1.09 | 0.86, 1.37
| Medium | | 77 | 0.96 | 0.72, 1.26
| High | | 39 | 0.64 | 0.43, 0.92
| ^a^Fecundability density ratio adjusted for employment, smoking, alcohol consumption, irregular menstrual cycles, and number of children (recent contraceptive use not found to be a confounder).; TTP among women with high formaldehyde exposure, by glove use
| | | N | FDR^a^ | 95% CI
| Gloves | | 22 | 0.79 | 0.47, 1.23
| No gloves | | 17 | 0.51 | 0.28, 0.92
| ^a^Fecundability density ratio adjusted for employment, smoking, alcohol consumption, irregular menstrual cycles, and # children.
| TTP among women with high formaldehyde exposure and phenol (when included in same model)^a^
| | | N | FDR^b^ | 95% CI
| Phenol | | 68 | 1.56 | 0.93, 2.53
| Formaldehyde | | NR^c^ | 0.57 | 0.37, 0.85
| ^a^All women exposed to phenols were also exposed to formaldehyde, but not vice versa.; Fecundability density ratio adjusted for employment, smoking, alcohol consumption, irregular menstrual cycles, and # children.; ^c^Not reported.
Reference: Zhu et al. (2005); Cohort study, Denmark; Population: Exposed were female laboratory technicians, identified through the Danish National Birth Cohort, who had only held one job (n = 1,069); 1^st^ interview in June 1997−February 2003 (at week 12−25 of gestation); excluded women with endometriosis, ovarian or cervical cancer, unplanned or partly planned pregnancies, and included only 1^st^ pregnancy in study period for each woman (final n = 829, 77.5% of initial study cohort); 8.6% ≥35 years old, 13.9% smoker during 1^st^ trimester; 29.3% previous spontaneous abortion. Referents were teachers identified in same manner; n = 6,250 (73.9% of initial cohort of 8,461); 12.7% ≥35 years old, 20.1% smoker during 1^st^ trimester; 31.1% previous SA; Exposure: Queried at gestation week 12–25 (median week 17). Self-report on laboratory work processes during pregnancy and 3 months before, including frequency and use of protective measures.; Exposure index (EI) calculated as exposure level × frequency of work contact, using scores for exposure level and frequency:; Formaldehyde exposure level (low = 1, medium = 2), assigned by study researchers as follows:; Low: human blood and tissue processing, work with experimental animals, work with microorganisms; medium: preparation of slides for microscopy. No work processes were identified considered to involve high exposure to formaldehyde.; Frequency: everyday = 4, several times per week = 3, several days per month = 2, and rarely = 1. Exposure Index categories: 1−5 and ≥6; Methods: Self-report of TTP (4 categories: 0−2 months, 3−5 months, 6−12 months, and >12 months); Fecundability ratios analyzed using discretetime survival analysis (complementary log-log link); comparisons between laboratory technicians and referents (teachers) and among laboratory technicians; covariates in model see results.; Evaluation: ^a^; Low confidence; Categorized TTP (decreased precision), missed pregnancies that ended before 1^st^ interview.; Variation in probability or intensity of formaldehyde exposure possible for work processes across different types of labs and high likelihood of exposure misclassification (likely underestimating the effect estimate), did not account for large proportion of participants who used protective measures to prevent inhalation exposure. JEM was not validated for formaldehyde. | Fecundability ratio for 1^st^ pregnancies among 829 laboratory technicians, by formaldehyde exposure index
| EI | N | cFR | aFR^a^ | 95% CI
| 1–5 | 112 | 1.0 | 0.92 | 0.69, 1.22
| ≥6 | 74 | 1.18 | 1.03 | 0.74, 1.43
| ^a^aFR: adjusted for maternal age, gravidity, smoking, prepregnancy BMI, and paternal job (also evaluated history of spontaneous abortion and alcohol consumption).
| | N | cFR | aFRb | 95% CI
| Teacher | 6,250 | 1.00 | 1.00
| Labtechnician | 829 | 1.01 | 0.98 | 0.86, 1.13
| ^b^FRa: adjusted for maternal age, gravidity, smoking, prepregnancy BMI, and paternal job (also evaluated history of spontaneous abortion and alcohol consumption).

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.8).

Abbreviations: TTP = time to pregnancy; CI = confidence interval; EI = exposure index; JEM = job-exposure matrix; FDR = fecundability density ratio; BMI = body mass index.

* Converted study exposure values are presented in [italics]. Conversion factors for formaldehyde in air (at 25°C): 1 ppm = 1.23 mg/m^3^.

###### Spontaneous abortion

Two medium confidence studies provide evidence (see Table 3-54) that formaldehyde exposure to female workers is associated with an increased risk of spontaneous abortion. A third low confidence study contributed information about exposure-response patterns, which was included as a consideration in the synthesis. These studies examined diverse occupational groups exposed to different combinations of chemical exposures and products containing formaldehyde (wood working, cosmetology, research laboratories). Relatively high odds ratios (ORs) of 2–3.5 in the highest exposure categories were observed (Taskinen et al., 1994; Taskinen et al., 1999; John et al., 1994). Studies of hospital, nursing, or medical employees generally did not report an association with formaldehyde exposure, although these low confidence studies tended to use less precise exposure assessment methods, a major limitation that reduced the sensitivity of these studies.

All of the studies defined spontaneous abortion, also called miscarriage, as a pregnancy loss before the 20th week of gestation. Spontaneous abortions were ascertained retrospectively, primarily using questionnaires, and in several studies these self-reports were included for analysis only if they could be verified using additional information. Some studies included all eligible spontaneous abortions recalled by participants (Taskinen et al., 1999; Steele and Wilkins, 1996). These studies had greater sensitivity (ascertained early pregnancies prior to clinical recognition). Other studies identified spontaneous abortions directly from a hospital discharge register (Lindbohm et al., 1991; Hemminki et al., 1985), an approach that avoids the limitations of recall bias but is prone to under ascertainment of early recognized losses that do not merit medical attention (Wilcox, 2010).

All of the studies focused their exposure assessments on the first trimester of pregnancy (women). The assignment of formaldehyde exposure during this period of susceptibility for spontaneous abortion (Wilcox and Horney, 1984) was less certain for two low confidence studies, possibly resulting in misclassification and reduced study sensitivity (Steele and Wilkins, 1996; Lindbohm et al., 1991).

Two medium confidence studies conducted analyses or provided details to evaluate potential confounding by coexposures and found that formaldehyde exposure posed an independent risk. One study adjusted for other coexposures in the workplace that also posed a possible risk of spontaneous abortion (John et al., 1994). In this evaluation of cosmetologists, an adjusted OR of 2.1 was reported for use of formaldehyde-based disinfectants (95% CI 1.0, 4.3). Taskinen et al. (1999) evaluated previous spontaneous abortions reported by female woodworkers, all of whom had a live birth, using unconditional logistic regression, and adjusted for age, employment, smoking, and alcohol consumption. No associations were observed for exposure to phenol, organic solvents, wood, and other dusts. Because formaldehyde was the only exposure associated with spontaneous abortion, these other work exposures were not confounders in this analysis. Potential confounding was identified to be a limitation for a study of laboratory technicians (Taskinen et al., 1994). This study observed a strong association between formalin exposure at a frequency of 3–5 days per week and spontaneous abortion (OR = 3.5; 95% CI 1.3, 7.5), but most of the participants exposed to formalin also reported exposure to xylene, which also was strongly associated with spontaneous abortion (OR = 3.1; 95% CI 1.3, 7.5). Although potentially confounded by xylene, the results of this study were compared to those of John et al. (1994) and Taskinen et al. (1999) to assess a potential bias away from the null. Other studies did not provide information to evaluate confounding by coexposures and did not provide risk estimates adjusted for coexposures.

ORs for spontaneous abortion risk in relation to maternal formaldehyde exposure are plotted in Figure 3−30 and are grouped by industry. The three studies indicate that maternal formaldehyde exposure is associated with risk of spontaneous abortion among woodworkers, laboratory workers, and cosmetologists (Taskinen et al., 1994; Taskinen et al., 1999; John et al., 1994). Two studies evaluated multiple exposure groups and found that stronger associations were observed among women in the highest exposure groups (OR range 3.2–3.5). Although, Taskinen et al. (1994) did not control for xylene exposure, which also was associated with spontaneous abortion risk, the magnitude of the OR among laboratory workers with the most frequent exposure was comparable to the two higher confidence studies.

Figure 3-30 Risk of spontaneous abortion associated with maternal occupational formaldehyde exposure

OR and number of exposed cases are presented for each study. Taskinen et al. (1999) and John et al. (1994) were medium confidence studies, and Taskinen et al. (1994) was a low confidence study due to potential confounding possibly resulting in bias away from the null (shaded). The number of exposed cases was not reported by Taskinen et al. (1999). A range of formaldehyde exposure concentrations experienced in specific industries is presented. Formaldehyde concentration ranges reported or cited by the authors are presented (Taskinen et al., 1994; Taskinen et al., 1999), or were obtained from the literature for cosmetology (Tsigonia et al., 2010; Labrèche et al., 2003).

Table 3-54 Epidemiology studies describing effects on spontaneous abortion in relation to formaldehyde exposure

Study and design | Results
Reference: John et al. (1994) United States Case-control study; Population: 6,202 of 8,356 women (74%) in North Carolina cosmetology license registry responded to screening questionnaire; 1,249 of 1,696 women (74%) with eligible pregnancy (most recent pregnancy for which last menstrual period occurred between April 1983 and March 1988) completed detailed questionnaire. Data obtained on 191 of 267 eligible spontaneous abortions, and 1,058 of 1,429 eligible live births (1,696 total abortions and live births); 87% white, 92% high school education, 65% income <$20,000, mean age 25.9 years.; Exposure: Self-reported exposure through mailed questionnaire to formaldehyde-based disinfectant products during first trimester. Other measures of exposure intensity: number of customers, number and type of chemical services performed per week, number of hours per day spent standing, disinfection products used, and glove use.; Methods: Three spontaneous abortions were excluded because no positive pregnancy test or subsequent medical care was reported. Women working ≥35 hrs/week as cosmetologists, with or without use of formaldehyde disinfectants, were compared to women working in other jobs (referent) during first trimester, and cosmetologists working with formaldehyde disinfectants were compared with those who did not. Multivariate unconditional logistic regression.; Evaluation: ^a^; Medium confidence; Selection of most recent eligible pregnancy (potential underascertainment); no ambient measurements; adjustment for previous pregnancy loss may introduce bias. | Spontaneous abortions in 7.8% of most recent pregnancies; mean gestational age for spontaneous abortion: 9.8 weeks.
| Spontaneous abortion among women working full-time (≥35 hr/week) during 1^st^ trimester
| | | # SA | OR^a^ | 95% CI
| Other jobs | | 26 | 1.0 | Referent
| Cosmetology work, no formaldehyde-based disinfectant use | | 16 | 0.8 | 0.4, 1.6
| Cosmetology work, use 51 of formaldehyde-based disinfectant | | 51 | 1.7 | 1.0, 3.0
| ^a^Adjusted for mother’s age at conception, previous pregnancy loss, and cigarette smoking.
| Spontaneous abortion among women working full-time (≥35 hr/week) as cosmetologists during 1^st^ trimester
| formaldehyde disinfectant use | | # SA | OR^a^ | 95% CI
| No | | 14 | 1.0
| Yes | | 47 | 2.1 | 1.0, 4.3
| ^a^Adjusted for variables listed above and other work exposures (hours worked, hours standing, chemical services, formaldehyde-based disinfectant, alcohol-based disinfectant, and nail sculpturing).
| ORs increased with standing ≥8 hours a day and the number of chemical services/week. Previous pregnancy loss, ≥3 pregnancies, and cigarette smoking were more prevalent among women with spontaneous abortion.
Reference: Taskinen et al. (1999); Retrospective cohort study, Finland; Population: Women (n = 3,772), recruited from a woodworkers’ union and other businesses involving wood processing. 1,094 women eligible (born between 1946 and 1975, had a live birth at age 20–40 years during 1985–1995, had worked in the wood processing industry for at least 1 month, and had first employment in the wood processing industry beginning at least 6 months before the index pregnancy). The first eligible pregnancy was the index pregnancy. Information about personal characteristics, pregnancies, and exposures was collected from mailed questionnaires; response rate 64%. After other exclusions (primarily infertility history, unknown TTP, and contraceptive failure), the final sample included 602 women.; Exposure: Questionnaire on exposure to specific agents including hours/week during the period pertaining to TTP. Exposures during critical exposure period(s) for spontaneous abortion were not estimated. Mean daily exposure to formaldehyde was based on measurements taken at the factories where the women worked during the early 1990s or, if measurements unavailable, from comparable industries. Sampling protocol was not described.; Formaldehyde concentrations were obtained from comparable industries for 46, 31, and 61% of women in low, medium, and high exposure categories, respectively.; Formaldehyde concentration in factories by exposure category:; Low mean 0.07 ppm (0.086 mg/m^3^)^a^, range 0.01 to 0.03 ppm (0.012 to 0.37 mg/m^3^);; Medium mean 0.14 ppm (0.17 mg/m^3^), range 0.05 to 0.4 ppm (0.062 to 0.49 mg/m^3^);; High mean 0.33 ppm (0.41 mg/m^3^), range 0.15 to 1.0 ppm (0.18 to 1.2 mg/m^3^); Other chemicals with measurements: phenol, organic solvents, wood dust, other dusts.; Methods: Self-reported spontaneous abortions occurring prior to the index pregnancy and at the same workplace were evaluated.; Unconditional logistic regression, ORs, adjusted for age, employment, smoking, and alcohol; # exposed cases not reported.; Evaluation: ^a^; Medium confidence; Uncertainty regarding exposure measurements with regard to critical exposure period(s) for spontaneous abortion; excluded women with no live birth (missing spontaneous abortions to women with no live births). | For 52 pregnancies with report of previous spontaneous abortion and same place of employment for both events (95% CI)
| Exposure | | OR | | 95% CI
| Low | | 2.4 | | 1.2, 4.8
| Medium | | 1.8 | | 0.8, 4.0
| High | | 3.2 | | 1.2, 8.3
| Organic solvents, dusts, wood dusts, and phenols were not associated with spontaneous abortions.
Reference: Taskinen et al. (1994); Finland, Retrospective case-referent; Population: Sampled from payroll of state lab personnel (1970, 1975−1986), Finnish Union of Laboratory Assistants (1987), and Register of Employees Occupationally Exposed to Carcinogens (1979−1986); Exposure: Self-reported exposure from mailed questionnaire. Substances listed in questionnaire or open-ended question; Frequency:; Rare: 1−2 days/week; Frequent: 3+ days/week; Reviewed by two occupational hygienists blinded to case status; 8/10 cases and 5/7 referents exposed to formalin were also exposed to xylene.; Methods: Participants responded to mailed questionnaire regarding occupational exposure, health status, medications, contraception use, smoking, and alcohol consumption during 1st trimester (824 returned/1,000 mailed (82.4%)). Sample linked to Hospital Discharge Register and database of spontaneous abortions treated at hospital outpatient clinics, 1973−1986. Cases: 206 women aged 20−34 years with one spontaneous abortion during study period; 329 referents: 2/case selected from registered births and not a case, matched on age (24 months) and year of end of pregnancy. Logistic regression for matched data adjusting for parity, previous miscarriage, febrile diseases during pregnancy, used contraception at beginning of pregnancy, alcohol consumption, and employment status.; Evaluation: ^a^; Low confidence (↑); Adjustment for parity and previous miscarriage may introduce bias; lack of adjustment for xylene, an exposure associated with the spontaneous abortion and formalin exposure. Evaluation of increasing frequency of use a strength. | Spontaneous abortion risk by frequency of formaldehyde exposure
| Exposure | | Cases/Referent | OR | 95% CI
| Employed | | | 0.9 | 0.5, 1.7
| Laboratory | | | 1.4 | 0.9, 2.2
| Formalin
| 1−2 days/week | | 12/28 | 0.7 | 0.3, 1.4
| 3−5 days/week | | 11/8 | 3.5^a^ | 1.1, 11.2
| ^a^p < 0.05
| Other substances also were associated with spontaneous abortion during 1^st^ trimester; xylene 3−5 days/week (OR 3.1; 95% CI 1.3, 7.5), toluene 3−5 days/week (OR 4.7; 95% CI 1.4, 15.9).
Reference: Steele and Wilkins (1996) United States; Population: 85% of 2,978 eligible women graduating from U.S. colleges of veterinary medicine during 1970−1980, mean age 36.1 years, 96.2% White; 1,444 women reported 3,098 pregnancies, 2,375 after graduation.; Exposure: Self-reported job exposure to specific listed chemical or physical agents (yes, no, don’t know). Exposed pregnancy defined if estimated time of conception was during the reported years of a job for which exposure also was reported.; Definitions of exposure:; 1. Job classification associated with the index pregnancy (type of clinical practice). Referent pregnancies: women unemployed when pregnancies began.; 2. Specific chemical and physical agents. Referent: employed women reporting no exposure to that agent or unemployed while pregnant. Thirteen exposure categories examined: disinfectants, antibiotics, animal insecticides, formaldehyde, non-DES hormones, solvents, radiation, diethylstilbestrol, nonhalothane anesthetics, halothane, antineoplastics, heavy metals, and ethylene oxide.; Methods: Self-reported (via mailed questionnaire in 1987) pregnancy and employment history. Evaluated eligible pregnancies (live births, induced abortions, spontaneous abortions) in relation to postgraduate employment. Spontaneous abortion defined as fetal death prior to 20 weeks. Unconditional multiple logistic regression of spontaneous abortion in relation to clinical practice type or self-reported exposures adjusting for maternal age, gravidity, history of spontaneous abortion, history of smoking, and alcohol use.; Evaluation: ^a^; Low confidence; No information on intensity and frequency of formaldehyde exposure, which would likely be variable among veterinarians (exposure misclassification–decreased sensitivity). Adjustment for gravidity and previous spontaneous abortion may introduce bias. | 264 (11.1%) spontaneous abortions.
| Analysis limited to women holding only one job at the time of conception (1,813 pregnancies).
| Spontaneous abortions in veterinarians with self-reported exposure to formaldehyde, adjusted^a^ OR (95% CI)
| Clinical practice | | Exposed pregnancies (N) | OR | 95% CI
| All types | | 172 | 0.9 | 0.6, 1.5
| All small animal | | 115 | 1.1 | 0.6, 2.0
| ^a^adjusted for age, history of spontaneous abortion, gravidity, smoker, drinker.
Reference: Hemminki et al. (1982) Finland; Retrospective cohort; Population: Female nursing staff working in sterilizing units (exposed) or auxiliary units (referent) in all (approx. 80) general hospitals; 50 exposed pregnancies, 1,100 unexposed pregnancies.; Exposure: Exposure to sterilizing agents (formaldehyde, ethylene oxide, glutaraldehyde) at beginning of pregnancy (1960−1980) assigned by supervising nurse. Blind to case status; 50 formaldehyde-exposed pregnancies out of 545 total exposed group (9%).; No air monitoring conducted.; Methods: Questionnaire mailed to current supervising nurses to identify nurses exposed to chemical sterilizing agents and nurses not exposed to sterilizing agents, X-rays, or anesthetic gases; response in exposed 91.6%; referent 90.6%.; Spontaneous abortions, 1960−1980, identified via questionnaire sent to nurses (self-report); compared to Finland hospital discharge register, 1973−1979.; Spontaneous abortion rate (compared to total pregnancies, live births, induced abortions, spontaneous abortions), logistic regression adjusting for age, parity, decade of pregnancy, smoking habits, alcohol, and coffee consumption.; Evaluation: ^a^; Low confidence; Adjustment for parity may introduce bias. Assumed sterilant use was same throughout period; no information on intensity and frequency of formaldehyde exposure (exposure misclassification–decreased sensitivity); no adjustment for other sterilants. Small number of exposed cases. | Adjusted spontaneous abortion rate (total pregnancies (N) and adjusted rate) among women not exposed and exposed to formaldehyde during pregnancy
| | Not Exposed | | Exposed
| Agent | N | Rate | N | Rate
| HCHO^a^ | 1,100 | 8.3 | 50 | 8.4
| ^a^Some individuals used more than one sterilizing agent
| Adjusted rates among women exposed to ethylene oxide were higher 16.1% versus 7.8%, p < 0.01.
Reference: Hemminki et al. (1985) Finland; Case-control study; Population: Pregnancies during 1973−1979 among women who worked in anesthesia surgery, intensive care, operating room, or internal medicine departments of a general hospital.; Exposure: Exposure assessment via questionnaire sent to head nurses at all general hospitals in Finland. For each study subject, requested occupation and exposure (yes, no) to any of the listed substances during a stated 3-month period (1^st^ trimester); blind to case status.; Listed substances were anesthetic gases (nitrous acid, halothane, other), sterilizing agents (ethylene oxide, glutaraldehyde, formaldehyde), disinfectant soaps (requested names), cytostatic drugs, and X-rays. Included information about job: shift work, night shift, rotating etc. Occupation identified during 1^st^ trimester for 87.1% cases and 87.8% controls. Information on employment and exposure obtained for 81% of case:control sets.; No air monitoring conducted.; Methods: Spontaneous abortions identified by linking Finnish Hospital Discharge Register with Central Register of Health Care Personnel; 217 cases identified from register as treated for spontaneous abortion 1973−1979 (ICD8 643 & 645).; Controls (n = 571) were nurses who gave birth to a healthy infant 1973−1979 and other pregnancies who were not cases. Selected three controls per case, matched on age (± 1.5 years), among nurses from same hospital as case. Relationships between spontaneous abortion and formaldehyde analyzed using an unmatched crude analysis.; Evaluation: ^a^; Low confidence; No information on intensity or frequency (exposure misclassification–decreased sensitivity); very small number of exposed cases. | Spontaneous abortion; Crude rate (# cases/# all pregnancies): 8.3%; not different from Finnish rate: 8.4%
| Exposed pregnancies (#) (at least once per week) among cases and controls (unadjusted OR)
| Agent | Cases | | Controls | | OR
| | # | % | # | %
| HCHO | 6 | 3.7 | 24 | 5.2 | 0.6
| Exposure defined as whether subject used sterilizing agent or sterilized instruments

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.8). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Abbreviations: SA = spontaneous abortion; OR = odds ratio; CI = confidence interval; HCHO = formaldehyde.

###### Birth outcomes

The epidemiology literature is very limited regarding formaldehyde exposure and birth outcomes (see Table 3-55). One birth cohort study reported decreases of 0.044 and 0.056 in the z-scores for birth weight and head circumference, respectively, with each 1 µg/m^3^ unit increase in formaldehyde concentration measured in the mother’s homes at 34 weeks gestation (Franklin et al., 2019). Gestational age was not associated with exposure. The median concentration in the homes was 0.0028 mg/m^3^ and 23.3% of samples were below the LOD in this relatively small study. Another pregnancy cohort study in South Korea observed lower birth weights associated with increasing formaldehyde concentration measured at mid to late pregnancy (mean concentrations were 0.08 mg/m^3^), although the association for formaldehyde was not strong while the association for total volatile organic compounds (VOCs) was of greater magnitude. Total VOCs were correlated with formaldehyde levels (Chang et al., 2017). Another study of pregnant women in the southeastern United States, rated as low confidence, reported an association of biparietal diameter, suggestive of intrauterine growth retardation, with personal formaldehyde exposure >0.037 mg/m^3^, both measured in the second trimester (Amiri and Turner-Henson, 2017). Preterm birth and low birth weight were not associated with exposure to high formaldehyde concentrations among a cohort of male woodworkers in China (Wang et al., 2012).

An elevated association with congenital malformations and maternal exposure was reported by a limited set of low confidence studies among female hospital or laboratory workers (Zhu et al., 2006; Hemminki et al., 1985). The precision of the ORs was low, as indicated by the wide CIs generally overlapping 1.0. In addition, the studies evaluated associations for all, or major malformations grouped together. These outcomes may be etiologically distinct, so this lack of specificity limits the ability to interpret these results. The probability or frequency of exposure to formaldehyde likely was low in these studies, which would have limited the ability to detect differences across various exposure groups for these rare outcomes (Hemminki et al., 1985; Ericson et al., 1984).

Table 3-55 Epidemiology studies describing effects on prenatal growth and births outcomes in relation to formaldehyde exposure

Study and design | Results
Reference: Franklin et al. (2019); Birth cohort study, Australia; Population: Pregnant women, all nonsmokers, recruited prior to 18 weeks gestation. 305 of 373 recruited, 81.7% participation; Birth data available for 262 live births. N=129 males and N=133 females, gestational age 38.97 weeks (6 infants born at 36–37 weeks).; Exposure: Air monitoring in homes at 34 weeks gestation, 7-day sampling duration using validated passive samplers in bedroom and living room. LOD 2.4 µg/m^3^; used LOD/2 for values <LOD.; House Median (range) 2.81 (LOD–17.33) µg/m^3^; 23.3% < LOD.; Methods: Gestational age (untransformed), birth weight, birth length and head circumference (all z-scores) obtained from birth records.; Evaluation: ^a^; Medium confidence; Uncertainties in exposure distribution due to proportion < LOD, and analysis as continuous variable. | Prenatal growth; Regression coefficients (95% CI) per µg/m^3^; Birth weight (z-score) −0.044 (−0.085, −0.004; p =0.033); Head circumference (z-score) −0.056 (p = 0.06); General linear models adjusted for maternal age, parity, maternal asthma, maternal diabetes, maternal hypertension, and season of birth. ETS and distance to roads evaluated but not included in final model.; No associations with gestational age or birth length (results not reported)
Reference: Chang et al. (2017) (Pregnancy cohort) South Korea; Population: Women were selected from hospital-based pregnancy cohort (n = 383), Mother and Childrens Environmental Health Study. Infants followed at 6 (n=262), 12 (n=234), 24 (n=199), and 36 months (n=92).; Exposure: Personal formaldehyde measurements during mid- or late pregnancy, 3 days. Categorized into two groups below and above the 75^th^ percentile and also continuous variable with log transformation. Mean (SD) 0.082 (0.052) mg/m^3^, geometric mean 0.067, 75^th^ percentile 0.106 mg/m^3^. Correlation between TVOCs and formaldehyde 0.22, p<0.01.; Methods: Birth weight from medical records; Age-specific postnatal weight at 6, 12, 24, and 36 months by gender using growth standard for Korean children.; Evaluation: ^a^; Medium confidence; Hospital-based cohort, notable attrition over time | Birth weight; Regression coefficient (SE); −37.98 (39.55) per 1 log unit change in formaldehyde (p value = 0.34); Multiple linear regression adjusted for maternal age, body mass index, education level, parity, infant’s gender, and gestational age at delivery.
| Postnatal weight; Mean difference by exposure group, p value, at
| 6 months | | | −0.09, 0.529
| 12 months | | | −0.25, 0.149
| 24 months | | | −0.04, 0.860
| 36 months | | | 0.22, 0.702
| Multiple linear regression adjusted for birth weight with maternal age, gestational age at delivery, pre-pregnancy BMI, educational level, parity, and infant’s gender plus, air cleaner use and house age.; Association with greater magnitude observed for TVOCs for birth weight and postnatal weight; Prevalence LBW 2.5%; Prevalence gestational age <37 weeks, 3.6%
Reference: Amiri and Turner-Henson (2017); Cross-sectional study (Southeastern United States); Population: Pregnant women in 2nd trimester (n = 140) recruited from obstetrics and gynecology clinics with no history of chronic disease or high-risk pregnancy, 19 - 40 years old, 46% White, 37% African American, 16% other race. Participation 63% (n = 88).; Exposure: Personal exposure during 2^nd^ trimester, vapor monitor badges, 24-hour period, detection limit 0.003 ppm. Mean (SD) 0.04 (0.06) ppm; 0.049 (0.074) mg/m^3^; Methods: Ultrasonographic biometry during 2nd trimester for head circumference, abdominal circumference, femur length, biparietal diameter, estimated fetal weight, and ratio of abdominal circumference to femur length. Measurements in mm converted to percentiles using gestational age and the Hadlock formulas.; Evaluation: ^a^; Low confidence; Convenience sample, sampling frame not described. Lower participation rate. Small sample size. Reference population for BPD measure was not appropriate for >50% of participants. | Ultrasonographic biometry; BPD percentile lower by 0.271% among infants with maternal exposure >0.03 ppm (0.037 mg/m^3^), (p < 0.013).; Multiple linear regression adjusted for race. Maternal age and fetal sex were not associated.; Other biometric measures were not associated with formaldehyde exposure.
Reference: Hemminki et al. (1985); Case-control study, Finland; Population: Pregnancies during 1973−1979 among women who worked in anesthesia surgery, intensive care, operating room, or internal medicine departments of a general hospital.; Exposure: Exposure assessment via questionnaire sent to head nurses at all general hospitals in Finland. Reported occupation for each name and whether exposed to listed substance during a stated 3-month period (1^st^ trimester); blind to case status.; Substances were anesthetic gases (nitrous acid, halothane, other), sterilizing agents (ethylene oxide, glutaraldehyde, formaldehyde), disinfectant soaps (requested names), cytostatic drugs, and X-rays. Included information about job: shift work, night shift, rotating etc. Occupation identified during 1^st^ trimester for 87.1% cases and 87.8% controls. No air monitoring conducted.; Methods: Congenital malformations identified by linking with Register of Congenital Malformations; 46 cases 1973−1979.; Controls were nurses who gave birth to a healthy infant 1973−1979 and other pregnancies were not cases. Selected three controls per case, matched on age (± 1.5 years), among nurses from same hospital as case. Congenital malformation controls: 128.; Evaluation: ^a^; Low confidence; No information on intensity or frequency (exposure misclassification–decreased sensitivity); very small number of exposed cases. | Congenital Malformations; Exposed pregnancies (E) (at least once per week) and total pregnancies (T) among cases and controls (unadjusted OR)
| Agent | Cases | | Controls | | OR
| | E/T | % | E/T | %
| HCHO | 3/34 | 8.8 | 5/95 | 5.3 | 1.8
| Exposure defined as whether subject used sterilizing agent or used sterilized instruments; (only one nurse sterilized instruments)
Reference: Zhu et al. (2006); Cohort study, Denmark; Population: Source: Danish National Birth Cohort; 30−40% of all pregnant women in Denmark, 1st interview June 1997−February 2003; 1,025 of 1,069 pregnancies of laboratory technicians with one job at interview and 1st pregnancy; excluded induced abortions, hydatidiform mole, or unknown outcomes of pregnancy (95.9% of eligible); 9.7% ≥35 years old, 14.9% smoker during 1st trimester; 27.7% previous spontaneous abortion. Referent: 8,037 of 8,461 teachers; 14.6% ≥35 years old, 22.1% smoker during 1st trimester; 29.6% previous spontaneous abortion.; Exposure: Queried at gestation week 11–25 (median week 16). Self-report on laboratory work processes during pregnancy and 3 months before including frequency and use of protective measures. JEM: EI = Exposure level times Frequency of work contact; Exposure level: low (1), medium (2), and high (3); assigned by study researchers; For formaldehyde: low: human blood and tissue processing, work with experimental animals, work with microorganisms; medium: preparation of slides for microscopy. No work processes were identified with high exposure to formaldehyde.; Frequency: everyday (4), several times per week (3), several days per month (2), and rarely (1); EI categorized into two levels: 1−5 and ≥6. Methods: Cohort linked to National Hospital Register and Medical Birth Register, Cox regression and hazard ratios for late fetal loss and congenital malformations; laboratory technicians compared to teachers and comparisons within laboratory technicians. Adjusted for maternal age, history of spontaneous abortion, gravidity, prepregnancy BMI, smoking, paternal laboratory job, alcohol consumption, child’s sex (some models).; Evaluation:^a^; Low confidence (↓); Variation in probability or intensity of formaldehyde exposure possible for work processes across different types of labs, did not account for large proportion of participants who used protective measures to prevent inhalation exposure. JEM was not validated for formaldehyde. | ORs for 1st pregnancies among 991 laboratory technicians by formaldehyde exposure category (N, adjusted OR, [95% CI]).
| Exposure Index
| 0 | | 1–5 | | ≥6
| “Major” malformation
| 20, 1.0 | | 20, 1.2 (0.6, 2.1) | | 16, 1.5 (0.8, 2.9)
| Unexposed technicians were exposed to other work processes.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.8). Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Abbreviations: OR = odds ratio; EI = exposure index; BMI = body mass index; JEM = job-exposure matrix.

##### Male reproductive toxicity

Four epidemiology studies were available regarding formaldehyde exposure and male reproductive toxicity (see Table 3-56). Two studies (medium confidence) of male woodworkers in China from one research group reported associations with lower sperm motility (total and progressive) (Wang et al., 2015), delayed fertility and spontaneous abortion (Wang et al., 2012). Eligible participants were of Han Chinese ethnicity and were occupationally exposed for at least 24 months. A detailed exposure assessment involved formaldehyde measurements and individual information regarding workplace, work tasks, time spent at work tasks, and duration of employment. Progressive motility and total motility were inversely associated with formaldehyde exposure index, a cumulative measure of exposure, and a strong association with this exposure metric also was observed in logistic models of below-normal values of these motility measures. For example, ORs of 2.58 and 3.41 were found for progressive motility less than 32% in the low and high exposure groups, respectively, compared to the community-based referent group. In another study, no statistically significant differences in sperm counts or percentage of abnormal sperm were observed in an underpowered, low confidence study of autopsy workers (Ward et al., 1984).

Wang et al (2012) reported odds ratios of 2.83 for a TTP > 12 months (95% CI:1.08, 7.41) and 1.92 (95% CI:1.10, 3.33) for spontaneous abortion associated with formaldehyde exposure among male woodworkers in China. Elevated odds ratios also were observed for preterm birth, low birth weight and birth defects although these risk estimates were imprecise. Lindbohm et al. (1991) reported no association with spontaneous abortion identified from a nationwide hospital discharge register in relation to male formaldehyde exposure assessed using census data. There was a high likelihood of exposure misclassification using this assessment method, which reduced the sensitivity of the study (i.e., judged as low confidence) to identify an association with developmental endpoints.

Table 3-56 Epidemiology studies describing male reproductive toxicity in relation to formaldehyde exposure

Study and design | Results
Reference: Wang et al. (2015) China; Prevalence; Population: Woodworkers; N = 124 participated (62.3%), N = 10 with missing semen data, aged 23−40, Chinese Han ethnicity, occupational exposure at least 24 months; excluded men living in newly built or recently remodeled house, men with genital malformations or other chronic disease; N = 81 (40.5%) recruited referent group age-matched, male Han volunteers from same area (salesmen and clerks), N = 5 with missing semen data.; Exposure: Sampling: 25-minute samples at three times on one workday, same day as questionnaire. Exposure information based on workplace, work tasks, work duration, and time (referenced (Wang et al., 2012)). Exposure index based on formaldehyde concentration (mean of three samples) multiplied by exposed work time during workday and exposure duration (years). Two categories with cutpoint at median.; Concentrations: Exposed 0.22–2.91 mg/m^3^, exposure index 4.54–195.08, median 56.55; referent 0–0.02 mg/m^3^. Measurement and adjustment for other contaminants was not described (e.g., phenols).; Methods: Semistructured interview questionnaire, genital examination, semen collection (2−7 days after abstinence), and analysis (within 2 weeks of formaldehyde sampling); parameters were semen volume, sperm concentration, total sperm count, sperm progressive motility, total sperm motility, and kinematic parameters (WHO, 2010). Linear regression Ln-transformed semen parameters and formaldehyde exposure and logistic regression of abnormal semen parameters.; Models adjusted for age, BMI, education, income, smoking, alcohol, and abstinence duration.; Evaluation: ^a^; Medium confidence; Other workplace exposures in woodworking industry (solvents) have been associated with sperm motility but not accounted for; however, otherwise strong design and analysis, including evaluation of increasing exposure-response relationship. | Regression analysis of sperm parameters and formaldehyde exposure index
| | | | β | 95% CI
| Volume (mL)^a^ | | | −0.02 | −0.08, 0.03
| Concentration (10^6^/mL)^a^ | | | −0.02 | −0.19, 0.14
| Total sperm count^a^ | | | −0.20 | −0.68, 0.29
| Sperm progressive motility (%)^b^ | | | −0.19 | −0.25, −0.12
| Total motility^b,c^ | | | −0.23 | −0.30, −0.16
| ^a^Relative percentage change; ^b^Absolute change; ^c^Progressive motility plus nonprogressive motility
| No association with kinematic parameters
| Logistic regression of below-normal values of sperm parameters and formaldehyde exposure index (below and above median, compared to referent (N = 76)
| | | | Low (N = 57) | High (N = 57)
| Semen volume (<1.5 mL) | | | 1.83 (0.63, 5.36) | 2.28 (0.75, 6.91)
| Concentration (<15 × 106/mL) | | | 1.67 (0.33, 8.43) | 1.25 (0.21, 7.35)
| Total sperm count (<39 × 10^6^) | | | 1.59 (0.45, 5.61) | 1.73 (0.49, 6.15)
| Progressive motility (<32%) | | | 2.58 (1.11, 5.97) | 3.41 (1.45, 7.92)
| Total motility (<40%) | | | 3.21 (1.24, 8.28) | 4.84 (1.83, 12.81)
Reference: Wang et al. (2012), Retrospective cohort, 2007−2009; China; Population: Woodworkers; 302 eligible of 1,035 married men, aged 23−40, Chinese Han ethnicity, occupational exposure at least 24 months; excluded 733 couples living in newly built or recently remodeled house before and during pregnancy, couples who never tried to conceive, couples with genital malformations or other chronic disease, wives with occupational exposure to reproductive toxicants, pregnancies before husband’s formaldehyde exposure and data incomplete; 305 of 816 recruited referent group age-matched, married male Han volunteers from same area (salesmen and clerks); Exposure: Mean daily exposure for each worker: Reported workplace, work tasks, and hour per day exposed to formaldehyde; concentration monitored three times during different periods.; Daily exposure index: Mean formaldehyde concentration times proportion of exposed work time during work day multiplied by 100 [cited exposure assessment by Taskinen et al. (1999)].; Daily mean concentration categorized in low (n = 151) and high (n = 151), equal number in each group.; Formaldehyde sampling details not provided (concentrations, sampling protocols, sampling locations, etc.). TWA formaldehyde concentrations were not reported. Measurement and adjustment for other contaminants was not described (e.g., dust, phenols); Methods: Semistructured interview questionnaire. Most recent pregnancy; TTP: # months of unprotected intercourse leading to pregnancy; spontaneous abortion defined as termination of pregnancy prior to 20th week gestation; preterm: <37 weeks; low birth weight: 2,500 g; major structural birth defects.; Evaluation: ^a^; Spontaneous abortion; Medium confidence; Other workplace exposures in woodworking industry (solvents) have been associated with spontaneous abortion but not accounted for; Analysis of most recent pregnancy: possible selection for live births (time-lapse bias) and impact of gravidity on spontaneous abortion; Time-to-pregnancy; Medium confidence; Exposure levels not reported (but robust assessment method).; Dichotomized TTP in analysis (low sensitivity). | OR (95% CI) associated with paternal formaldehyde exposure
| | | | Exposed: Referent | High: Low
| TTP >12 months | | | 2.83^a^ (1.08, 7.41) | 2.29 (0.78, 6.77)
| Spontaneous abortion | | | 1.92^b^ (1.10, 3.33) | 1.78 (0.88, 3.62)
| Preterm birth | | | 1.25^c^ (0.55, 2.84) | 0.85 (0.28, 2.60)
| Low birth weight | | | 1.26 (0.59, 2.66) | 1.0 (0.37, 2.74)
| Birth defects | | | 2.61^d^ (0.79, 8.65) | 1.26 (0.33, 4.78)
| ^a^Adjusted for: BMI, alcohol; ^b^Adjusted for: Cigarette smoking; ^c^Adjusted for: Education; ^d^Adjusted for: Alcohol
| No confounders were identified for low birth weight
| Logistic regression model adjusted for confounders identified through univariate analyses. Confounders considered: age, BMI, education, income, smoking, alcohol, and frequency of intercourse. The numbers of exposed and referent cases were not presented.
Reference: Lindbohm et al. (1991) Finland; Registry linkage; Population: All Finnish women with diagnosis of spontaneous abortion (ICD−8 643, 645), induced abortion (ICD−8 640−642), or birth (ICD−8 650−662) between 1973 and 1982 were identified using the nationwide Hospital Discharge Register and hospital outpatient records.; Information on occupation and industry of women and their husbands, and SES (women only), was obtained from Finnish national censuses from 1975 to 1980. Excluded pregnancies among women <12 years or >50 years of age, and those lacking data on occupation, industry, or SES. Final study population included 99,186 pregnancies ending Jan. 1–Dec. 31, 1976 or May 1, 1980−Apr. 30, 1981.; Exposure: Job-exposure classification developed by two industrial hygienists using combinations of occupation and industry with similar type of exposure. Identified jobs held during census period close to period of susceptibility. List of toxic agents associated with job groups developed using air sampling data from Finnish occupational health agency and register of employees occupationally exposed to carcinogens.; Exposure categories:; 1. Not exposed; 2. Potential, low: jobs with low levels but high prevalence of exposure, jobs without exposure data but in register of occupational exposure to carcinogens, or jobs with high level but unknown prevalence of exposure; 3. Moderate or high: jobs with levels ≥TLV, or periodically ≥TLV and high prevalence; Paternal exposure to any mutagenic agent:; Not exposed: 87,616; Potential, low: 9,930; Moderate/high: 1,640; Methods: Logistic regression models were used to evaluate association between spontaneous abortion and paternal occupation or industry during period of susceptibility (spermatogenesis 80 days prior to conception, or 1^st^ trimester).; Evaluation: ^a^; Low confidence; Industry/occupation coding has low specificity; potential exposure misclassification and imprecise assignment of exposure period to period of spermatogenesis relevant to identified pregnancy. | Spontaneous abortion rate 8.8% (including induced abortions in denominator).
| Spontaneous abortion risk by paternal exposure to formaldehyde^a^
| Group | N | Cases | OR^b^ | 95% CI
| Not exposed | 87,616 | 7,772 | 1.0
| Potential, low | 1,212 | 110 | 1.1 | 0.9, 1.4
| Mod/High | 596 | 54 | 1.0 | 0.8, 1.4
| ^a^Among 25 evaluated exposures.; ^b^Adjusted for maternal age, socioeconomic status, and maternal exposure to potential reproductive hazards.
| Paternal exposures to solvents (petroleum refineries), rubber production solvents, rubber chemicals, and ethylene oxide were associated with increased odds of spontaneous abortion (p < 0.05).
Reference: Ward et al. (1984) Texas; Population: Exposed: 11 male pathologists and coworkers at university autopsy service. Matched referent: 11 staff and students in medical branch; matched on sex, age, tobacco, alcohol, and recreational drug use.; Exposure: Area and personal breathing zone samples; exposures episodic, maximum 5.8 ppm (7.13 mg/m^3^),* LOD = 0.12 mg/m^3^ TWA 0.61–1.32 ppm (0.75–1.62 mg/m^3^); Methods: Morning semen samples every 2−3 months. Sperm counts and morphology (percentage abnormal); three samples per subject at 2- to 3-month intervals; mean value analyzed; Pearson correlation coefficients.; Evaluation: ^a^; Low confidence; Small sample size; uncertainty regarding reliability of morphology scoring. | Sperm abnormalities (mean [SD]) by exposure group
| | | | Exposed | Referent
| Count^a^ | | | 62.9 (49.9) | 87.4 (75.0)
| percentage abnormal | | | 44.5 (13.4) | 53.5 (16.2)
| ^a^ millions/cc of semen
| Differences between exposed and referent were reported to be not statistically significant.

Organized by study confidence, then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.8).

Abbreviations: BMI = body mass index; TWA = time-weighted average; SD = standard deviation.

Converted study exposure values are presented in (italics). Conversion factors for formaldehyde in air (at 25°C): 1 ppm = 1.23 mg/m^3^.

##### Summary of Human Evidence Synthesis Judgments on Developmental and Reproductive Toxicity

###### Female Reproductive or Developmental Toxicity

The following factors, in particular the consistent effects in the available medium confidence studies, were influential to the synthesis judgment that the human studies on female reproductive or developmental toxicity provide moderate evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: Decreased fecundability among a working population with maternal exposure in a medium confidence study. Increased spontaneous abortion risk among working populations with maternal exposure in two medium confidence studies and one low confidence study. Decreased birth weight and head circumferences in two medium confidence studies. Low confidence studies were mixed, but most were null; the low confidence null findings did not reduce certainty.
- Dose-Response: Evidence of dose-dependence in effects on fecundability and spontaneous abortion risk was shown by a medium confidence study and one low confidence study.

###### Male Reproductive Toxicity

The following factors led to the synthesis judgment that the human studies on male reproductive toxicity provide slight evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: Two medium confidence studies from the same research group observed effects on several sperm parameters, time-to-pregnancy longer than 12 months, increased risk of spontaneous abortion, and an indication of postnatal effects.
- Coherence: Several biologically related endpoints were unchanged, reducing certainty.

#### Animal Studies

This section provides a separate discussion of the available experimental animal studies on developmental toxicity, female reproductive toxicity, and male reproductive toxicity, which are separately summarized in Tables 3-57, 3-58, and 3-59, respectively. For each of these three categories of health effects, the discussion is organized based on the types of endpoints evaluated, and the evidence tables are organized by endpoint, study confidence (if applicable; see Appendix B.3.8 for details), species, and descending publication year.

Two of the studies that assessed developmental toxicity evaluated a standard battery of developmental endpoints following inhalation exposure of formaldehyde to rats on gestation days (GDs) 6−15 (Martin, 1990) or GD 6−20 (Saillenfait et al., 1989) (i.e., during [at a minimum] the period of major organogenesis in the rat). Both of these studies had limitations. Martin (1990) employed robust exposure methods but failed to report methodological details and quantitative results. In contrast, Saillenfait et al. (1989) was well reported, but rodents were exposed to formalin (including 10% methanol), which introduces substantial uncertainty regarding the role of formaldehyde in the observed effects. Importantly, of these two studies, only Saillenfait et al. (1989) identified adverse developmental outcomes. There are also reports identifying developmental effects resulting from formaldehyde exposures administered throughout gestation to rats (Sheveleva, 1971; Senichenkova, 1991a; Senichenkova and Chebotar, 1996a; Pushkina et al., 1968; Monfared, 2012; Kum et al., 2007; Kitaev et al., 1984; Gofmekler et al., 1968). Evidence that inhalation exposures to formaldehyde might affect the female reproductive system in rats is limited to three studies that are considered to be low confidence (Wang et al., 2013; Maronpot et al., 1986; Kitaev et al., 1984). However, all of the available animal studies of female reproductive toxicity and developmental toxicity had serious methodological limitations, most notably poor methods used in conducting formaldehyde exposures, and are all interpreted with low confidence.

Additionally, studies in rodents reported that formaldehyde adversely affects the male reproductive system after inhalation exposures of varied durations. Some of the studies were considered as high to medium confidence (Vosoughi et al., 2012; Vosoughi et al., 2013; Sarsilmaz et al., 1999; Ozen et al., 2002; Ozen et al., 2005); however, all of the available medium and high confidence studies exposed animals to high formaldehyde concentrations (>5 mg/m^3^). The other available studies, including many testing lower formaldehyde levels, had methodological limitations that resulted in their consideration as low confidence studies (Zhou et al., 2006; Zhou et al., 2011a; Zhou et al., 2011b; Xing et al., 2007a; Han et al., 2015; Golalipour et al., 2007; Appelman et al., 1988). Studies examining developmental immunotoxicity following gestational exposure and developmental neuropathology following postnatal exposure were discussed previously (see Sections 3.2.3 and 3.3.1, respectively).

##### Developmental toxicity

The formaldehyde database contains results of studies that evaluated effects on pre- or postnatal development following inhalation exposures (see Table 3-57). The evidence table is organized by several major manifestations of developmental toxicity (U.S. EPA, 1991): survival, growth, and morphological development. (Functional developmental toxicity is not addressed here.) Because all of the developmental toxicology studies have limitations that result in low confidence ratings, studies within each category are presented in alphabetical order by author in the table. The results of these studies are presented in Figure 3-31.

Figure 3-31 Animal studies evaluating the effects of formaldehyde inhalation exposure on developmental toxicity

Low confidence animal studies of developmental toxicity are presented. As no high or medium confidence experimental animal studies were identified (see Appendix B.3.8), the available studies are organized by endpoint, then species, then by timing of exposure (e.g., premating [premat.] or pregestational [pregest.]; gestational [g= gestational day]; or postnatal [p = postnatal day] exposure). Filled shapes indicate statistical significance, as indicated by the study author (black), or ≥10% change from control groups (gray). The size of the points reflecting the sample size for that particular exposure group (larger size = larger n). The low confidence experiments are shown on a gray background, as the identified study limitations substantially reduce confidence in the reliability of the results; these low confidence experiments contribute very little to the weight of evidence for developmental toxicity.

###### Fetal survival

Decreased prenatal survival following developmental exposures was observed as increased preimplantation loss by Kitaev et al. (1984) at 1.5 mg/m^3^ and by (Sheveleva, 1971) at 0.5 mg/m^3^ or increased postimplantation loss at 0.5 mg/m^3^ by Senichenkova and Chebotar (Senichenkova and Chebotar, 1996b). The evidence for these outcomes across the available studies is inconsistent (see Table 3-57). For example, only Kitaev et al. (1984), Senichenkova et al. (1991b), and Sheveleva et al. (1971) treated the dams during the preimplantation period (i.e., GD 0−6 in rats) and specifically indicated that preimplantation loss was examined. Kitaev et al. (1984) found degenerated embryos on GD 3, but not GD 2 (which could reasonably have been the result of continued exposure of the embryos to stressors resulting from formaldehyde exposure and may not have been an inconsistency in response); however, increased preimplantation loss was not observed by (Senichenkova, 1991b). The increased postimplantation loss reported by Senichenkova and Chebotar (1996a) was not observed by Senichenkova et al. (1991b), in spite of the fact that these two studies used the same procedures and exposure levels, nor was it reported by Sheveleva et al. (1971), Saillenfait et al. (1989), or Martin et al. (1990). The reason for these varied responses is unknown, although they might have been influenced by differences in study protocols or study conduct that are not transparently elucidated in the publications. Because of limitations in the description of methods or results for most of these studies, it is not possible to conduct an in-depth evaluation of this issue.

###### Fetal and postnatal growth

Evidence of decreased or delayed fetal or early postnatal growth was noted in a number of studies, but a consistent pattern of response was difficult to identify due to differences in study protocols and study quality. Following gestational formaldehyde exposure, significant 24−32% decreases in fetal body weight (accompanied by alterations in placental weight and ultrastructural conformation of the placenta) were observed in mice at exposure levels of ≥5.68 mg/m^3^ by Monfared et al. (2012). Saillenfait et al. (1989) reported significant fetal weight decreases in rats of 5% at 24.6 mg/m^3^ and of 19−21% at 49.2 mg/m^3^. However, fetal weight deficits were not noted by Martin et al. (1990) at exposure levels up to 12.3 mg/m^3^ or by Sheveleva (1971) at 5 mg/m^3^. Conversely, significantly increased fetal body weight was noted in some studies following gestational exposure to comparatively lower exposure levels of formaldehyde, e.g., Gofmekler et al. (1968) (7% and 13% increased fetal weight at 0.012 and 1 mg/m^3^, respectively) and Senichenkova et al. (1991b) (a 5% increase at 0.5 mg/m^3^). It is possible that such findings might be more subtle signals for developmental disruption of metabolic regulation and function. At 7.38 mg/m^3^, Kum et al. (2007) found significant 31% decreases in rat pup weights at 3 weeks of age following in utero and lactational exposures and significant 14% decreases at 6 weeks of age (i.e., around the time of puberty) following 6 weeks of exposure starting at birth. Body weight decreases (9%) in young adult rats after 6 weeks of exposure starting at 4 weeks of age did not reach statistical significance. Notably, the same outcome did not occur when adult rats on the study were treated for 6 weeks. These findings suggest the possibility of a life stage-related susceptibility to formaldehyde exposures. Gofmekler et al. (1968) reported significantly decreased neonatal relative liver and lung weights (~5 and 20%, respectively) following gestational exposures to ≥0.012 mg/m^3^. A 2−3-day increase in the mean postnatal day on which incisor eruption occurred, another indicator of delayed postnatal growth, was reported in rat pups that had been exposed in utero to 0.5 mg/m^3^ (Senichenkova, 1991a).

###### Fetal morphological development

Morphological alterations of fetuses exposed in utero were reported in three studies (Senichenkova, 1991a; Senichenkova and Chebotar, 1996a; Saillenfait et al., 1989). Senichenkova et al. (1991b) and Saillenfait et al. (1989) observed delayed skeletal ossification of various bones, some of which are generally consistent with developmental delays, at 0.5 and 49.2 mg/m^3^, respectively. However, Senichenkova et al. (1991b) noted significantly increased metatarsal and metacarpal ossification centers; this finding suggests more advanced ossification states rather than a delay in development and is consistent with the finding of increased fetal weights in that study. Senichenkova et al. (1991b) also reported an increase in litters with uncharacterized internal organ anomalies at 0.5 mg/m^3^. The only outcome specific to reproductive system development was a reported ~20% increase in “cryptorchidism” by Senichenkova and Chebotar (Senichenkova and Chebotar, 1996a) and Senichenkovae et al. (1991b) at 0.5 mg/m^3^; this was interpreted as evidence of a delay in fetal (i.e., 1^st^ stage) testes descent. No study in the available database specifically examined the second stage of postnatal testes descent in pups. Thus, there is no evidence to determine if the observed effect represented a developmental delay or if it was related to disruptions in male reproductive tract ontogeny, which is dependent on normal levels of fetal testicular testosterone and on the expression of insulin-like hormone-3 (insl3) in fetal Leydig cells (Klonisch et al., 2004). This abnormality was not observed in any other study in the formaldehyde database; however, no single or multigeneration reproduction studies were available, and it is with this type of protocol that such a finding would more likely be detected. Martin et al. (1990) did not report any structural anomalies resulting from inhalation exposures during gestation up to exposure levels of 12.3 mg/m^3^.

The potential influence of maternal toxicity on developmental findings was considered in the review of the available data. For several studies, information on maternal toxicity was not reported (Senichenkova, 1991a; Senichenkova and Chebotar, 1996b; Monfared, 2012) although for these studies, it is not known whether (1) maternal toxicity was not assessed or (2) maternal toxicity was assessed, but results were not reported. Kum et al. (2007) measured maternal body and liver weight but found no treatment-related effects. In Kitaev et al. (1984), increased luteinizing hormone (LH) or follicle-stimulating hormone (FSH) levels were observed in dams at 0.5 and 1.5 mg/m^3^, with compromised preimplantation survival noted at the highest exposure level. Although the maternal hormonal alterations could have been related to the embryo loss, there was no confirmation in other studies. Gofmekler et al. (1968) noted increased gestation duration at 0.012 and 1 mg/m^3^, with corollary evidence of increased newborn body and organ weights at those exposure levels. Sheveleva et al. (1971) reported evidence suggesting maternal toxicity at 5 mg/m^3^, including a decreased threshold of neuromuscular excitability, increased rectal temperature, and increased hemoglobin in dams; however, developmental toxicity (i.e., increased preimplantation loss) was observed at both 0.5 and 5 mg/m^3^. Martin et al. (1990) reported significantly decreased maternal weight gain and food consumption only at the highest exposure level (12.3 mg/m^3^), but no developmental toxicity was observed in the study. In the Saillenfait et al. (1989) study, significantly decreased maternal body-weight gain was observed only at the highest exposure level (49.2 mg/m^3^); however, significantly decreased fetal weight was observed at both 24.6 and 49.2 mg/m^3^. Thus, in the limited developmental toxicity database available for evaluation, there was little evidence that maternal toxicity was a major contributing factor to observations of developmental toxicity.

Overall, the database for the evaluation of developmental toxicity (survival, growth, and morphological alterations) consisted of weak (low confidence) studies that had methodological limitations, primarily lack of information about the test substance or the described use of formalin, with known or presumed methanol coexposures. Effects on fetal survival, pre- or postnatal growth, or morphological alterations were observed in several studies and sometimes more than one rodent species, and maternal toxicity did not appear to be a confounding influence. However, inconsistencies in response were also observed, and clear dose-response relationships were not discernable. Additional animal experiments using stronger study designs are needed to thoroughly assess the effect of formaldehyde exposure on development.

Table 3-57 Summary of developmental effects observed in animal studies following inhalation exposure to formaldehyde

Reference and study design^a^ | Results^b^ and exposure levels (mg/m^3^)
Low confidence (all animal studies of developmental toxicity)
Fetal survival
Reference: Senichenkova and Chebotar (1996a); Rats (mongrel, strain not reported), 29/group; 4 hr/day, GD 1–19 (C-section GD 20); 0 or 0.5 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article, exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5]
| Mean postimplantation loss^c^ | | | | - | 29%
Reference: Senichenkova (1991b); Rats (white mongrel), 137 dams total, ≈46 dams/group; 4 hr/day, GD 1−19 (C-section GD 20); 0 or 0.5 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5]
| Number (%) preimplantation loss | | | | 38/381 (10.0) | 25/304 (8.2)
| Number (%) postimplantation loss | | | | 26/343 (7.6) | 12/279 (7.3)
| Mean preimplantation loss | | | | − | −3%
| Mean postimplantation loss | | | | − | −15%
Reference: Martin (1990); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6−15; 0, 2.46, 6.15, 12.3 mg/m^3^; Test article: Paraformaldehyde; Maternal tox: Significantly decreased maternal body-weight gain and food consumption at 12.3 mg/m^3^; Main limitations: Inadequate reporting of methods and quantitative results. | Report states that there was no evidence of decreased fetal survival; no data were presented.
Reference: Saillenfait et al. (1989); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6−20; 0, 6.15, 12.3, 24.6, or 49.2 mg/m^3^; Test article: Formalin; Maternal tox: Significantly decreased maternal body-weight gain at 49.2 mg/m^3^; Main limitation: Formalin. | | [underlined: 0] | [underlined: 6.15] | [underlined: 12.3] | [underlined: 24.6] | [underlined: 49.2]
| Mean total fetal loss/litter^c^ | − | −33 | 0 | 0 | 0%
Reference: Kitaev et al. (1984); Rats (Wistar), 200 females total; 4 hr/day, 5 days/week, for 4 months; 0, 0.5 or 1.5 mg/m^3^; Test article: Not characterized; Maternal tox: Altered LH and FSH levels in treated dams; Main limitations: Test article NC; limited description of methods. | | | | [underlined: 0] | [underlined: 0.5] | [underlined: 1.5]
| Number (percentage) degenerated embryos GD 2 (n = 5−8) | | | 2 (5.1) | 3 (3.8) | 5 (10.2)
| Number (percentage) degenerated embryos GD 3 (n = 5−9) | | | 3 (4.4) | 4 (9.1) | 10 (14.9)
Reference: Sheveleva (1971); Rats (mongrel, strain not reported), 15/group terminated GD 20, 6/group littered; 4 hr/day, GD 1–19; 0, 0.5, or 5 mg/m^3^; Test article: Not characterized; Maternal tox: Decreased threshold of neuromuscular excitability, rectal temperature, and hemoglobin in dams at 5 mg/m^3^; Main limitations: Test article NC; exposure generation, animal strain/source NR; limited description of methods. | | | | [underlined: 0] | [underlined: 0.5] | [underlined: 5]
| Mean preimplantation loss^c^ | | | - | 50 | 70%
| Mean postimplantation loss^c^ | | | - | 0 | 0%
Fetal and postnatal growth
Reference: Monfared (2012); Mice (Balb/C), 10/group; 8 hr/day, GD 6–16 (C-section GD 17); 0, 5.68, 11.38, or 22.76 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article NC; maternal tox: NR. | | | [underlined: 0] | [underlined: 5.68] | [underlined: 11.38] | [underlined: 22.76]
| Mean fetal weight (g) | | - | −24^*^ | −27^*^ | −32%^*^
| Mean placental weight (g) | | - | 35^*^ | 57^*^ | 39%^*^
| Thickness of placental trophoblastic basement membrane (nm) | | - | 148^*^ | 177^*^ | 203%^*^
| Thickness of placental labyrinth interhemal membrane (μm) | | - | 45^*^ | 42^*^ | 49%^*^
Reference: Kum et al. (2007); Rats (Sprague Dawley), 6/group; 8 hr/day, 7 days/week, for 6 weeks; starting at GD 1, PND 1, Week-4, or Adult; 0 or 7.38 mg/m^3^; Test article: Formalin; Maternal tox: Not reported; Main limitations: Formalin; limited description of methods; maternal tox NR. | | | | | [underlined: 0] | [underlined: 7.38]
| Decreased pup weight (g) (3-week old pups that were exposed in utero and during lactation) | | | | - | −31%^*^
| Decreased pup weight (g) (6-week old pups that were exposed during lactation and for 3 weeks postweaning) | | | | - | −14%^*^
| Decreased young adult weight (g) (10-week old young adults that were exposed starting at 4-weeks of age) | | | | - | −9%
| Mature adult weight (g) (6-week exposure to adult rats) | | | | - | 7%
Reference: Senichenkova (1991b); Rats (white mongrel), 137 dams total, ≈46 dams/group; 4 hr/day, GD 1-19 (C-section GD 20); 0 or 0.5 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5]
| Mean fetal body weight (g) | | | | - | 5%^*^
| Mean fetal length (mm) | | | | - | 0%
| Mean day of upper incisor eruption | | | | - | 17%^*^
| Mean day of lower incisor eruption | | | | - | 25%^*^
Reference: Martin (1990); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6–15; 0, 2.46, 6.15, 12.3 mg/m^3^; Test article: Paraformaldehyde; Maternal tox: Significantly decreased maternal body-weight gain and food consumption at 12.3 mg/m^3^; Main limitations: Inadequate reporting of methods and quantitative results. | Report states that fetal weights were not affected by treatment; no data were presented.
Reference: Saillenfait et al. (1989); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6–20; 0, 6.15, 12.3, 24.6, or 49.2 mg/m^3^; Test article: Formalin; Maternal tox: Significantly decreased maternal body-weight gain at 49.2 mg/m^3^; Main limitation: Formalin. | | [underlined: 0] | [underlined: 6.15] | [underlined: 12.3] | [underlined: 24.6] | [underlined: 49.2]
| Mean fetal body weight/litter – male | - | −1 | −2 | −5^*^ | −21%^*^
| Mean fetal body weight/litter – female | - | 1 | 0 | −3 | −19%^*^
Reference: Sheveleva (1971); Rats (mongrel, strain not reported), 15/group terminated GD 20, 6/group littered; 4 hr/day, GD 1–19; 0, 0.5, or 5 mg/m^3^; Test article: Not characterized; Maternal tox: Decreased threshold of neuromuscular excitability, rectal temperature, and hemoglobin in dams at 5 mg/m^3^; Main limitations: Test article NC; exposure generation, animal strain/source NR; limited description of methods. | | | | [underlined: 0] | [underlined: 0.5] | [underlined: 5]
| Mean fetal weight (g) | | | - | 0 | 3%
| Mean fetal length (mm) | | | - | 0 | 0%
Reference: Gofmekler et al. (1968); Rats (strain not specified), 12 females/group; Continuous exposure 10–15 days prior to mating and throughout gestation; 0, 0.012, or 1 mg/m^3^; Test article: Not characterized; Maternal tox: Increased duration of gestation at both dose levels; Main limitations: Test article NC, exposure generation, animal strain/source NR; limited description of methods; limited reporting. | | | | [underlined: 0] | [underlined: 0.012] | [underlined: 1]
| Mean newborn weight (g) | | | - | 7^*^ | 13%^*^
| Mean relative neonatal lung weight (mg/10 g BW) | | | - | −20^*^ | −19%^*^
| Mean relative neonatal liver weight (mg/10 g BW) | | | - | −5^*^ | −6%^*^
Fetal morphological development
Reference: Senichenkova and Chebotar (1996a); Rats (mongrel, strain not reported), 29/group; 4 hr/day, GD 1–19 (C-section GD 20); 0 or 0.5 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5]
| Mean percentage litters with hydronephrosis | | | | - | 5%
| Mean percentage litters with cryptorchidism | | | | - | 21%
Reference: Senichenkova (1991b); Rats (white mongrel), 137 dams total, ≈46 dams/group; 4 hr/day, GD 1–19 (C-section GD 20); 0 or 0.5 mg/m^3^; Test article: Not characterized; Maternal tox: Not reported; Main limitations: Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5]
| Mean percentage fetuses with cryptorchidism | | | | - | 20%^*^
| Number of litters with internal organ anomalies | | | | 2 | 8%
| Mean number of litters with internal organ anomalies | | | | - | 914%^*^
| Number (percentage) embryos with ossification centers in the hyoid bone | | | | 145(100) | 61(91)^*^
| Mean number of metacarpal bone centers | | | | - | 13%^*^
| Mean number of metatarsal bone centers | | | | - | 9%^*^
Reference: Martin (1990); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6–15; 0, 2.46, 6.15, 12.3 mg/m^3^; Test article: Paraformaldehyde; Maternal tox: Significantly decreased maternal body-weight gain and food consumption at 12.3 mg/m^3^; Main limitations: Inadequate reporting of methods and quantitative results. | Report states that fetal incidences of major malformations, minor external and visceral anomalies, or minor skeletal anomalies were not affected by treatment; no data presented.
Reference: Saillenfait et al. (1989); Rats (Sprague Dawley), 25/group; 6 hr/day, GD 6–20; 0, 6.15, 12.3, 24.6, or 49.2 mg/m^3^; Test article: Formalin; Maternal tox: Significantly decreased maternal body-weight gain at 49.2 mg/m^3^; Main limitation: Formalin. | | [underlined: 0] | [underlined: 6.15] | [underlined: 12.3] | [underlined: 24.6] | [underlined: 49.2]
| Unossified sternebrae [fetal(litter) incidence] | 3(3) | 1(1) | 6(3) | 6(3) | 15(7)
| Unossified sternebrae [fetal percentage] | 0.9 | 0.4 | 1.9 | 2 | 4.4%
| Unossified sternebrae [litter percentage] | 12.5 | 4.8 | 13 | 14.3 | 29.2%

Within each category of effect, organized by study confidence then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: GD = gestational day; LH = luteinizing hormone; FSH = follicle-stimulating hormone; NC = not characterized; NR = not reported.

a Studies with gestational or lactational exposures and evaluation of pre- or postnatal developmental outcomes are included in this table.

b Response relative to control for mean data, or incidence data.

c Incidence data not reported.

* Statistically significant difference from control value (p < 0.05), as reported by the study author.

Study exposure levels converted from ppm to mg/m^3^ are presented in italics (1 ppm = 1.23 mg/m^3^).

##### Female reproductive toxicity

Information on female reproductive toxicity in the formaldehyde database of animal studies is minimal (see Table 3-58; Figure 3-32). For the three low confidence studies that noted effects on the female reproductive system, the test substance was either not characterized (Wang et al., 2013; Kitaev et al., 1984) or was reported to be formalin (Maronpot et al., 1986).

Figure 3-32 Animal studies evaluating female reproductive toxicity

As no high or medium confidence experimental animal studies were identified (see Appendix B.3.8), the available studies are organized by endpoint, species, and then by duration of exposure. Symbol shading indicates statistically significant (black) or ≥10% change (gray) from controls, and the size of the points reflects the sample size for that exposure group (larger size = larger n). The low confidence experiments are shown on a gray background, as the identified study limitations substantially reduce confidence in the reliability of the results; these low confidence experiments contribute very little to the weight of evidence judgments for female reproductive toxicity.

Uterine and ovarian hypoplasia was observed by Maronpot et al. (1986) in 100% of the mice on study at 49.2 mg/m^3^ following 13 weeks of inhalation exposure; the incidence of these findings was zero at the next lower exposure level of 24.6 mg/m^3^. Histopathological evaluation conducted by Wang et al. (2013) did not confirm these findings, but identified a significant decrease in the number and size of mature ovarian follicles with a concomitant increase in the number of atretic follicles, and disruptions in structural integrity of the ovary in rats after 8 weeks of formaldehyde exposure. Kitaev et al. (1984) reported a 56% increase in relative ovarian weight, accompanied by increased blood LH and FSH levels (11 and 36%, respectively) and significantly increased ovulation (not shown in evidence table), at the lowest dose tested (0.5 mg/m^3^) in rats following 4 months of inhalation exposure; these findings are suggestive of a treatment-related disruption of the hypothalamic-pituitary-ovarian (HPO) axis. At the highest dose tested in the same study (1.5 mg/m^3^), ovarian weights and LH levels were decreased by 33 and 17%, respectively, as compared to control, and FSH levels were statistically significantly increased (191%); these findings might represent evidence of direct ovarian toxicity and the consequences of disturbed early embryo development in addition to effects on the HPO axis. However, a lack of information about sample collection and analytical methods render it difficult to interpret these data with confidence. The nonmonotonic effect on ovarian weight observed by Kitaev et al. (1984) was not corroborated by Wang et al. (2013). The hormonal alterations observed by Kitaev et al. (1984) could have been related to increased preimplantation loss observed in that study or indicative of an adverse effect on female reproductive system integrity. Other evidence of hormonal disruption, such as 12% decreased estradiol (E2) levels observed by Wang et al. (2013), might have been related to the ovarian histopathology observed in that study.

Overall, as only low confidence animal studies of female reproductive toxicity were available, this points to the need for further evaluation of the female reproductive system following formaldehyde inhalation exposure, including an assessment of overall female reproductive function.

Table 3-58 Summary of female reproductive effects observed in animal studies following inhalation exposure to formaldehyde

Reference and study design^a^ | Results^b^ and exposure levels (mg/m^3^)
Low confidence (all animal studies of female reproductive toxicity)
Reference: Wang et al. (2013); Rats (SD), 10 females/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC | | | | | [underlined: 0] | [underlined: 0.5] | [underlined: 2.46]
Reference: Wang et al. (2013); Rats (SD), 10 females/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC | Mean serum E2 (ng/L)^c^ | | | | 0 | −2 | −12
Reference: Wang et al. (2013); Rats (SD), 10 females/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC | Mean ovarian weight (g)^c^ | | | | 0 | −2 | −8
Reference: Wang et al. (2013); Rats (SD), 10 females/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC | Ovarian histopathological findings at [underlined: 2.46] mg/m^3^ ^d^:; - Number and size of mature follicles significantly decreased; - Number of atretic follicles increased; - Vascular congestion, interstitial edema, structure disorder
Reference: Maronpot et al. (1986); Mice (B6C3F1), 10/sex/group; 6 hr/day, 5 days/week, for 13 weeks; 0, 2.46, 4.92, 12.3, 24.6 or 49.2 mg/m^3^; Test article: formalin; Main limitations: Formalin; limited reporting of methods and results. | | [underlined: 0] | [underlined: 2.46] | [underlined: 4.92] | [underlined: 12.3] | [underlined: 24.6] | [underlined: 49.2]
| Ovarian hypoplasia | 0/10 | NE | NE | NE | 0/10 | 10/10
| Uterine hypoplasia | 0/10 | NE | NE | NE | 0/9 | 9/9
Reference: Kitaev et al. (1984); Rats (Wistar), 200 females total; 4 hr/day, 5 days/week, for 4 months; 0, 0.5 or 1.5 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; limited description of methods. | | | | | [underlined: 0] | [underlined: 0.5] | [underlined: 2.46]
| Mean relative ovary weight^c^ | | | | 0 | 56 | −33
| Mean blood LH (mg/mL)^c^ | | | | 0 | 11 | −17
| Mean blood FSH (mg/mL)^c^ | | | | 0 | 36 | 191^*^
| Number (%) degenerated embryos GD 2 (n = 5–7) | | | | 2 (5.1) | 3 (3.8) | 5 (10.2)
| Number (%) degenerated embryos GD 3 (n = 5–9) | | | | 3 (4.4) | 4 (9.1) | 10 (14.9)

Organized by study confidence then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: NE = not evaluated.

a Studies that evaluated female reproductive system toxicity are included in this table. Studies are organized by endpoint, species, and lowest dose tested.

b Response relative to control for mean data, or incidence data.

c Data digitized using Grab It!™, Datatrend Software.

d Incidence data not reported.

* Statistically significant difference from control value (p < 0.05), as reported by the study author.

Study exposure levels converted from ppm to mg/m^3^ are presented in italics (1 ppm = 1.23 mg/m^3^).

##### Male reproductive toxicity

Fourteen studies in rodents assessed effects on the male reproductive system following inhalation formaldehyde exposure (see Table 3-59; Figure 3-33); although eight of the studies had substantial methodological limitations, 13 of the 14 studies demonstrated treatment-related effects. Of the available studies, only those by (Vosoughi et al., 2012; Vosoughi et al., 2013) (both of which reported data from the same cohort of mice; see footnote in Table 3-59), (Ozen et al., 2002; Ozen et al., 2005), Appelman et al. (1988), Sapmaz et al. (2018), and Sarsilmaz et al. (1999) administered paraformaldehyde to the test animals and provided adequate characterization of the exposure paradigm (note: Appelman et al. (1988) was classified as low confidence due to reporting concerns). The results of these paraformaldehyde studies are interpreted with high (Vosoughi et al., 2012; Vosoughi et al., 2013) and medium (Sarsilmaz et al., 1999; Sapmaz et al., 2018; Ozen et al., 2002; Ozen et al., 2005) confidence; however, the results of the remaining studies in this section are considered much less reliable (i.e., low confidence), based in part upon deficient exposure criteria (see Appendix B.3.8). Evaluations of male reproductive toxicity in the more reliable (e.g., medium, and high confidence) studies are constrained by a complete lack of testing at lower formaldehyde concentrations. Specifically, one medium confidence study (Sapmaz et al., 2018) tested a single concentration of 6.15 mg/m^3^ and one medium confidence study (Ozen et al., 2005) tested concentrations >6 mg/m^3^, while the remainder of the medium (Sarsilmaz et al., 1999; Ozen et al., 2002) and high (Vosoughi et al., 2012; Vosoughi et al., 2013) confidence studies only examined concentrations >12 mg/m^3^. These high levels of formaldehyde could introduce additional complications to interpretation, including potential reflex bradypnea. In this regard, Ozen et al. (2005) and Sarsilmaz et al. (1999) noted clinical signs of respiratory irritation or altered breathing rate, while Ozen et al. (2002) and (Vosoughi et al., 2012; Vosoughi et al., 2013) did not report such observations. Sapmaz et al. (2018) did not report observations consistent with reflex bradypnea at 6.15 mg/m^3^.

The evidence table is organized by outcomes of male reproductive toxicity, in order of the strength of the evidence: histopathology, sperm measures, gonadotropic hormone measures, organ weights, and reproductive function. Within each category, the studies are organized by high to low confidence, and then alphabetically within a confidence category. The available animal studies of male reproductive toxicity are illustrated in Figures 3-33 and 3-34, with Figure 3-33 presenting all of the studies and Figure 3-34 presenting in greater detail the studies interpreted with medium or high confidence.

Figure 3-33 Animal studies evaluating male reproductive toxicity

The available studies are organized into high (i.e., only Vosoughi et al., 2013) and medium confidence studies (panel A) and low confidence studies (panel B), then by endpoint, and then by species. Shaded symbols indicate statistically significant effects (p < 0.05 as reported by the study authors) unless otherwise noted, and the size of the points reflects the sample size for that exposure group (larger size = larger n). The low confidence experiments (panel B) are shown on a gray background, as the study limitations substantially reduce confidence in the reliability of the results; these low confidence experiments contribute very little to the weight of evidence judgments for male reproductive toxicity.

Figure 3-34 Medium and high confidence animal studies evaluating male reproductive toxicity

The available high and medium confidence studies are arrayed and organized by endpoint. ^1^Results are displayed as fold change from control animals (control responses at 1 are illustrated as a dashed line), with variability in both the controls and treatment groups represented by the quotient (ratio) of the 95% confidence intervals (CI), as calculated based on the method originally described by E.C. Fieller (Cox and Ruhl, 1966), which assumes Gaussian distributions. ^a^The serum T measure at 24 hr is presented from Vosoughi et al. (2013). ^b^Seminiferous tubule diameter was not significantly affected by formaldehyde exposure (p > 0.05) in Sapmaz et al. (2018), although in addition to the reduced thickness shown above, the authors also reported a significantly reduced percentage of intact tubules at both formaldehyde exposure timepoints (i.e., 71.1% in controls; 42.2% with 6.2 mg/m^3^ at 4 weeks; and 17.2% with 6.2 mg/m^3^ at 13 weeks). Notes: * = author-reported statistical significance (p ≤ 0.05). Vosoughi et al. (2013) reflects results from both the 2012 and 2013 studies (Vosoughi et al., 2012; Vosoughi et al., 2013), which report data from the same cohort of mice; (Ozen et al., 2002; Ozen et al., 2005) and Sarsilmaz et al. (1999) are studies from the same research group.

###### Testes and epididymides histopathology

Quantitative and qualitative histopathological findings in the testes of adult male rodents following from 10 days to 18 weeks of inhalation exposure were reported in one high confidence studies (Vosoughi et al., 2012; Vosoughi et al., 2013) and three medium confidence studies (Sarsilmaz et al., 1999; Sapmaz et al., 2018; Ozen et al., 2005) that used paraformaldehyde, and in five low confidence studies that used formalin (Zhou et al., 2006; Zhou et al., 2011a; Zhou et al., 2011b; Han et al., 2013; Golalipour et al., 2007). Alterations in germ cell number and integrity, statistically significant reductions in germinal epithelium thickness or seminiferous tubule diameter (5–30%), tubular atrophy, markers of disrupted spermatogenic process, and Leydig cell damage were observed. Epididymal findings (e.g., decreased tubule diameters or atrophy, epithelial alterations, or absence of sperm) in Zhou et al. (2011b) also indicated a disruption of spermatogenesis. One low confidence study in mice treated for 13 weeks (Maronpot et al., 1986) did not report any lesions of the male reproductive tract. Notably, while this study used formalin as the test article, this limitation would be expected to bias the study toward observing an effect; thus, there is no credible rationale for this negative outcome. However, evidence of treatment-related testicular pathology in the high confidence mouse study by (Vosoughi et al., 2012; Vosoughi et al., 2013) suggests that the absence of effects in Maronpot et al. (1986) is probably not attributable to a difference in species response, although any potential influence of animal strain on response is unknown.

###### Sperm measures

A significantly decreased sperm count of 44–49% was observed at 35 days post-treatment in a high confidence study of mice exposed to ≥12.2 mg/m^3^ paraformaldehyde for 10 days (Vosoughi et al., 2012; Vosoughi et al., 2013). In a low confidence study in rats, 10 mg/m^3^ formalin exposure significantly decreased sperm count by 38% with a 2-week exposure (Zhou et al., 2011a) and 77% with a 4-week exposure (Zhou et al., 2011b), demonstrating an increase in the magnitude of the response as the duration of exposure increased, with the exposure concentration level remaining constant. In a second low confidence study, Zhou et al. (2011a) reported a significant 13% reduction in sperm count at 2.46 mg/m^3^ after 60 days of formalin exposure, consistent with the interrelationship among concentration, exposure duration, and magnitude of response. These data provide evidence of the downstream effects of disruptions to spermatogenesis that are observed histopathologically.

In the same studies, sperm motility was significantly decreased (by 40–46%) in mice (Vosoughi et al., 2012; Vosoughi et al., 2013) and by 13–17% in rats (Zhou et al., 2011a; Zhou et al., 2011b) at exposure levels ≥10 mg/m^3^ paraformaldehyde or formalin, respectively, and significant abnormal sperm morphology was observed at the same exposure levels (Zhou et al., 2006; Vosoughi et al., 2012; Vosoughi et al., 2013). Statistically significant increases in abnormal sperm were also observed in the low confidence study by (Xing Sy, 2007; Xing et al., 2007b) after 4 weeks of formalin exposure at exposure levels >20 mg/m^3^. The alterations in sperm count, motility, and morphology reported by (Vosoughi et al., 2012; Vosoughi et al., 2013) achieved statistical significance at 35 days (but not at 24 hours) postexposure, demonstrating a biologically plausible temporal delay in the outcomes associated with disruption of spermatogenesis. Altered sperm measures are considered biomarkers of reduced fertility; however, with the exception of the high exposure study by (Xing Sy, 2007; Xing et al., 2007b) that identified a male-mediated reduction in viable conceptuses, the formaldehyde database does not include any studies that specifically assessed fertility measures.

###### Hormone measures

One high confidence study (Vosoughi et al., 2012; Vosoughi et al., 2013) and one medium confidence study (Ozen et al., 2005) that exposed rodents to paraformaldehyde found significant, dose-dependent decreases in serum testosterone (T). Vosoughi et al. (2012); Vosoughi et al. (2013) exposed mice to paraformaldehyde for 10 consecutive days and reported 32–49% decreases at 24 hours post-exposure and 10–15% decreases at 35 days postexposure. While this might suggest postexposure recovery or a compensatory process, there are no other studies that tested this possibility. Ozen et al. (2005) noted similar 40-65% decreases in serum T after exposing rats for 91 days to paraformaldehyde. Zhou et al. (2011a), a low confidence formalin study in rats, demonstrated nonsignificant decreases (up to 6%) in serum T after 60 days of exposure. The decreased serum testosterone levels observed by Ozen et al. (2005); (Vosoughi et al., 2012; 2013), and Zhou et al. (2011a) are biologically consistent with the Leydig cell pathology observed by (Vosoughi et al., 2012; 2013) and Sarsilmaz et al. (1999) because Leydig cells are the primary source of testosterone production in the testes. No other studies evaluated alterations in serum T levels following formaldehyde exposure.

Vosoughi et al. (2012); (2013) also reported a significant 15% decrease in serum LH at 24 hours postexposure but not at 35 days postexposure. In the same study, FSH levels were not affected at the 24-hour and 35-day assessment times.

###### Testes and epididymides weights

A treatment-related effect on testes weight is suggested by the available data. However, even though a number of studies examined testes and epididymides weights, the findings were neither consistent nor easily interpretable. Statistically significant decreased mean testes or epididymal weight of ≥ 20% magnitude was reported in three low confidence rat studies with inhalation exposures to 5–10 mg/m^3^ formalin for 2- or 4- weeks duration (Zhou et al., 2006; Zhou et al., 2011b; Han et al., 2013). Conversely, testis or epididymal weights were not decreased in two studies: one high confidence study that exposed mice to paraformaldehyde for 10 days at up to 24.4 mg/m^3^ (Vosoughi et al., 2012; 2013) and one low confidence study that exposed rats for 60 days to 2.46 mg/m^3^ formalin (Zhou et al., 2011a). It is possible that these two studies did not detect effects on testes weight due to either the short exposure duration or the low-exposure level used, respectively.

Slight decreases in relative (to body weight) testes weight data in rats resulting from 12.2 or 24.4 mg/m^3^ paraformaldehyde exposures were reported by Ozen et al. (2002) and Sarsilmaz et al. (1999), medium confidence studies in rats. Findings at 4 weeks of exposure in each study were similar, with ≤3% decreases in relative testes weights (although statistical significance was reported by Ozen et al. (2002). Notably, following 13 weeks of exposure, Ozen et al. (2002) reported significant relative testes weight decreases compared to control of up to 10%, suggesting that there was a duration-related component to the response. A significant increase in mean relative (to body weight) testes weight following 53 weeks of paraformaldehyde exposure was reported for a low confidence study by Appelman et al. (1988); however, no quantitative data were presented in the study report. Appelman et al. (1988) attributed the relative testes weight increase to decreased body weights. Due to the absence of data on body weight, the veracity of this interpretation could not be assessed. The use of relative testes weights is typically not preferred for assessment of reproductive toxicity because testes weight has been shown to be generally conserved across 5–30% decreases in body weight (OECD, 2013). Insufficient information (on either the mean testes or body weights used in deriving the relative weight values) was provided in Ozen et al. (2002), Sarsilmaz et al. (1999), and Appelman et al. (1988) to fully evaluate the magnitude of the absolute testes weight effects.

###### Coherence of the animal evidence

Overall, the database for the evaluation of male reproductive toxicity (histopathology, sperm measures, gonadotropic hormone measures, organ weights, and reproductive function) included multiple high or medium confidence studies that provided coherent evidence of toxicity spanning biochemical, cellular, tissue, and functional levels. These findings were supported by evidence of male reproductive system toxicity in seven of eight of the remaining low confidence studies, although the interpretability of these findings is questionable, primarily due to a lack of information about the test substance or the described use of formalin. Specifically, effects on testes and epididymides histopathology were observed in a high confidence study in mice (Vosoughi et al., 2012; Vosoughi et al., 2013), two medium confidence studies in rats (Sarsilmaz et al., 1999; Ozen et al., 2005), and five low confidence studies in rats. The histopathological outcomes were supported by evidence of reduced serum testosterone in the high confidence mouse study (Vosoughi et al., 2012; Vosoughi et al., 2013) and a medium confidence rat study (Ozen et al., 2005), and alterations in sperm measures (count, motility, and morphology) in the high confidence study in mice (Vosoughi et al., 2012; Vosoughi et al., 2013) and four other low confidence studies in rodents, together demonstrating downstream consequences of the testes and epididymides histopathological lesions. Data on testes and epididymides weights provided some support, primarily from a medium confidence rat study (Ozen et al., 2002) and several low confidence studies, although the results overall were more mixed and difficult to interpret. Uncertainties remain due to a complete lack of high or medium confidence studies testing exposure levels <6 mg/m^3^, and observations potentially consistent with the occurrence of reflex bradypnea at >6 mg/m^3^ in two of the studies. However, the observed responses to high levels of formaldehyde provided a coherent pattern of effects in well-conducted studies performed across two international laboratories, using two rodent species, and varied durations, and, in some cases, demonstrating clear concentration-dependent responses of exposure. None of the studies in the database conducted an in-depth assessment of male reproductive function (e.g., including mating or fertility) or evaluated outcomes attributable to early-life exposures (such as would be assessed in a multigeneration reproduction study).

Table 3-59 Summary of male reproductive effects observed in animal studies following inhalation exposure to formaldehyde

Reference and study design^a^ | Results^b^ and exposure levels (mg/m^3^)
Testes and epididymides histopathology
High confidence
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Histopathological findings in treated males at 35 days postexposure^d^:; Testes: seminiferous tubule atrophy; Testes: increased space between germ cells; Testes: degeneration of Leydig cells; Testes: disintegration of seminiferous epithelial cells; Testes: degeneration of a number of seminiferous tubules
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | | | 0 | 12.2 | 24.4
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean seminiferous tubule diameter (μm)–24 hr postexposure | | - | −6 | −7%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean seminiferous tubule diameter (μm)–35 days postexposure | | - | −11^*^ | −13%^*^
Medium confidence
Reference: Sapmaz et al. (2018); Rats (Sprague-Dawley), 7 males/group; 8 hr/day, 5 days/week, for 4 or 13 weeks; 0 or 6.15 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Lack of detailed reporting on quantitative analyses of histopathology; small sample size. | | | 0 | 6.15 (4wk) | 6.15 (13wk)
| Mean germinal epithelial thickness (% change) | | - | −33.7%^*^ | −62%^*^
| Mean seminiferous tubule diameter (% change) | | - | −5.2% | −2.2%
| Percent intact tubules | | 71.7% | 42.2%^*^ | 17.2%^*^
Reference: Ozen et al. (2005); Rats (Wistar), 6 males/group; 8 hr/day, 5 days/week, for 91 days; 0, 6.15, or 12.3 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Limited and incomplete reporting; small sample size. | | | 0 | 6.15 | 12.3
| Mean seminiferous tubule diameters (μm) (n = 100 randomly selected tubules/group) | | - | −23^*^ | −26%^*^
Reference: Sarsilmaz et al. (1999); Rats (Wistar), 10 males/group; 8 hr/day, 5 days/week, for 4 weeks; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Inadequate information for quantitative analysis of histopathology data, | | | 0 | 12.3 | 24.6
| Mean Leydig cell quantity (100 sections total) | | - | −5^*^ | −6%^*^
| Leydig cell nuclear damage (picnotic, karyoretic, karyolitic) (% normal) | | - | −6 | −22%
Low confidence
Reference: Zhou et al. (2011b); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 4 weeks; 0, 0.5, 5, or 10 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; exposure generation NR; static chamber used; limited reporting of study results and group data. | Histopathological findings at 5 and 10 mg/m^3d^:; Testes: seminiferous tubule atrophy; Testes: decreased spermatogenic cells; Testes: oligospermic lumina
| | 0 | 0.5 | 5 | 10
| Mean seminiferous tubule diameter | - | −4 | −28^*^ | −30%^*^
Reference: Zhou et al. (2011a); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, or 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | Histopathological findings^d^:; Testes: seminiferous tubule atrophy; Testes: spermatogenic cells decreased; Testes: oligozoospermic lumina; Epididymis: oligozoospermic lumina
| | | 0 | 0.5 | 2.46
| Mean seminiferous tubule diameter (μm) | | - | −2 | −7%^*^
| Mean epididymal tubular diameter (caput) | | - | −1 | 0%
| Mean epididymal tubular diameter (cauda) | | - | 1 | −2%
Reference: Zhou et al. (2011b); Rats (Sprague Dawley), 12 males/group; 8 hr/day, 7 days/week, for 4 weeks; 0, 0.5, or 10 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | Histopathological findings^d^:; Atrophy of epididymal tubules; Disintegration of epididymal epithelium; Disorganization and denaturalization of epididymal epithelial cells; Epididymis: hyperemia of interstitial vasculature; Epididymis: oligozoospermic lumina
Reference: Golalipour et al. (2007); Rats (Wistar), 7 males/group; 18 weeks formaldehyde exposure; (1) 4 hr/day, 4 days/week; (2) 2 hr/day, 4 days/week; (3) 2 hr/day, 2 days/week; 0 or 1.85 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; open air exposures; N = 4/group. | Histopathological findings in group (3)^d^:; Increased spaces between germ cells in seminiferous tubules; Disrupted association between Sertoli and germinal cells; Histopathological findings in group (2)^d^:; Decreased germ cells and increased thickness of basal membrane in 75% of seminiferous tubules; Histopathological findings in group (1)^d^:; Severe decrease in germ cells in >85% of seminiferous tubules; Arrested spermatogenesis
| | (C) | (1) | (2) | (3)
| Mean seminiferous tubule diameter | - | −19^*^ | −8^*^ | −5%^*^
| Mean seminiferous tubule height | - | −21^*^ | −16^*^ | −12%^*^
Reference: Zhou et al. (2006); Rats (Sprague Dawley), 10 males/group; (1) 0 (gavage saline); (2) 10 mg/m^3^, 12 hr/day, 2 weeks; (3) 10 mg/m^3^, 12 hr/day, 2 weeks, plus 30 mg/kg-day oral vitamin E; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | Histopathological findings observed in formaldehyde exposure group (2)^d^:; Atrophy of seminiferous tubules; Decreased spermatogenic cells; Disintegrated and sloughed seminiferous epithelial cells; Edematous interstitial tissue with vascular dilation and hyperemia; Azoospermic seminiferous tubule lumina
Reference: Maronpot et al. (1986); Mice (B6C3F1), 10/sex/group; 6 hr/day, 5 days/week, for 13 weeks; 0, 2.46, 4.92, 12.3, 24.6 or 49.2 mg/m^3^; Test article: Formalin; Main limitations: Formalin; limited reporting of methods and results. | No observed effect of treatment on testes histopathology
Sperm measures
High confidence
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | 24-hours Post-exposure: | | 0 | 12.2 | 24.4
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean epididymal sperm count (10^6^/mL) | | - | −18 | −22%
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean progressive motility (%) | | - | −7 | −18%
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean immotile sperm (%) | | - | 33 | 56%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Sperm viability (%) | | - | −8 | −14%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean normal morphology (%) | | - | −7 | −7%
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | 35-days Post-exposure:
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean sperm count (10^6^/mL) | | - | −44^*^ | −49%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean progressive motility (%) | | - | −40^*^ | −46%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean immotile sperm (%) | | - | 129^*^ | 170%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Sperm viability (%) | | - | −26^*^ | −34%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day for 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean normal morphology (%) | | - | −13^*^ | −16%^*^
Low confidence
Reference: Zhou et al. (2011a); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, or 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | 0 | 0.5 | 2.46
| Mean epididymal sperm count (× 10^6^) | | - | −2 | −13%^*^
| Mean percentage motile sperm | | - | −3 | −4%
| Mean percentage abnormal sperm | | - | 1 | 4%^*^
Reference: Zhou et al. (2011b); Rats (Sprague Dawley), 12 males/group; 8 hr/day, 7 days/week, for 4 weeks; 0, 0.5, or 10 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | 0 | 0.5 | 10
| Mean epididymal sperm count (× 10^6^)^e^ | | - | 3 | −77%^*^
| Mean percentage motile sperm^e^ | | - | −1 | −14%^*^
Reference: Xing Sy (2007); (Xing et al., 2007b); Mice (unspecified strain), 7 males/group; 2 hr/day, 6 days/week, for 4 weeks; 0, 20.79, 41.57, or 83.15 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; exposure generation, strain NR; high exposure levels. | | 0 | 20.8 | 41.6 | 83.2
| Percentage abnormal sperm | 6.5 | 9.5^*^ | 14.3^*^ | 16.2^*^
Reference: Zhou et al. (2006); Rats (Sprague Dawley), 10 males/group; (1) 0 (gavage saline);; (2) 10 mg/m^3^, 12 hr/day, 2 weeks;; (3) 10 mg/m^3^, 12 hr/day, 2 weeks, plus 30 mg/kg-day oral vitamin E; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | (1) | (2) | (3)
| Mean epididymal sperm count (10^7^/g epididymal wt) | | - | −38^*^ | −16%
| Mean percentage motile sperm | | - | −17^*^ | −11%
| Mean percentage abnormal sperm | | - | 13^*^ | 6%
Hormone measures
High confidence
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Postexposure assessments: | 0 | 12.2 | 24.4
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum T (ng/mL), 24 hours | - | −32^*^ | −49%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum T (ng/mL), 35 days | - | −10^*^ | −15%^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum LH (ng/mL), 24 hours | | | - | −15^*^
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum LH (ng/mL), 35 days | | | - | −5
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum FSH (ng/mL), 24 hours | | | - | −5
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean serum FSH (ng/mL), 35 days | | | - | −5
Medium confidence
Reference: Ozen et al. (2005); Rats (Wistar), 6 males/group; 8 hr/day, 5 days/week, for 91 days; 0, 6.15, or 12.3 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Limited and incomplete reporting; small sample size. | | | 0 | 6.15 | 12.3
| Mean (terminal) serum T (nmol/L) (n = 6) | | - | −40^*^ | −65%^*^
Low confidence
Reference: Zhou et al. (2011a); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, or 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | 0 | 0.5 | 2.46
| Mean (terminal) serum T (nmol/L) | | - | −1 | −6%
Testes and epididymides weights
High confidence
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Postexposure assessments: | | 0 | 12.2 | 24.4
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean testes weight (mg), 24 hr^e^ | | - | 2 | 7%
Reference: Vosoughi et al. (2012); Vosoughi et al. (2013)^c^; Mice (NMRI), 12 males/group; 8 hr/day, 10 days; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde | Mean testes weight (mg), 35 days^e^ | | - | −1 | 0%
Medium Confidence
Reference: Ozen et al. (2002); Rats (Wistar), 7 males/group; 8 hr/day, 5 days/week, for 4 weeks or 13 weeks; 0, 12.2, or 24.4 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Non-preferred results reporting; small sample size. | | | 0 | 12.2 | 24.4
| Mean relative testes weight (4 weeks) | | - | −2^*^ | −3%^*^
| Mean relative testes weight (13 weeks) | | - | −8^*^ | −10%^*^
Reference: Sarsilmaz et al. (1999); Rats (Wistar), 10 males/group; 8 hr/day, 5 days/week, for 4 weeks; 0, 12.3, or 24.6 mg/m^3^; Test article: Paraformaldehyde; Main limitations: Inadequate information for quantitative analysis of histopathology data. | | | 0 | 12.2 | 24.4
| Mean relative testes weight | | - | −1 | −4%
Low confidence
Reference: Zhou et al. (2011b); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 4 weeks; 0, 0.5, 5, or 10 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; exposure generation NR; static chamber used; limited reporting of study results and group data. | | 0 | 0.5 | 5 | 10
| Mean testes weight (g)^e^ | - | −3 | −24^*^ | −21%^*^
Reference: Zhou et al. (2011a); Rats (Sprague Dawley), 10 males/group; 8 hr/day, 7 days/week, for 60 days; 0, 0.5, or 2.46 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | 0 | 0.5 | 2.46
| Mean testes weight (g) | | - | −1 | −3%
| Mean epididymis weight (g) | | - | 4 | −2%
Reference: Zhou et al. (2011b); Rats (Sprague Dawley), 12 males/group; 8 hr/day, 7 days/week, for 4 weeks; 0, 0.5, or 10 mg/m^3^; Test article: Not characterized; Main limitations: test article, exposure generation NR; static chamber used. | | | 0 | 0.5 | 10
| Epididymis weight (g)^e^ | | - | −2 | −31%^*^
Reference: Zhou et al. (2006); Rats (Sprague Dawley), 10 males/group; (1) 0 (gavage saline);; (2) 10 mg/m^3^, 12 hr/day, 2 weeks;; (3) 10 mg/m^3^, 12 hr/day, 2 weeks, plus 30 mg/kg-day oral vitamin E; Test article: Not characterized; Main limitations: Test article NC, exposure generation NR; static chamber used. | | | (1) | (2) | (3)
| Mean testes weight (g)^e^ | | - | −22^*^ | −3%
Reference: Appelman et al. (1988); Rats (Wistar), 40 males/group; 6 hr/day, 5 days/week, for 13 or 52 weeks; 0, 0.123, or 12.3 mg/m^3^; Test article: Paraformaldehyde; Main limitations: No indication if histopathology performed on male reproductive organs; quantitative testes weights not presented. | Significant increase in mean relative testes weight at 53 weeks at 10 ppm (12.3 mg/m^3^) reported (no data were presented); effect was attributed by study author to decreased body weight.
Reproductive function
Low confidence
Reference: Xing Sy (2007); (Xing et al., 2007b); Mice (unspecified strain), 7 males/group, mated with untreated females; 2 hr/day, 6 days/week, for 4 weeks; 0, 20.79, 41.57, or 83.15 mg/m^3^; Test article: Not characterized; Main limitations: Test article NC; exposure generation, strain NR. | | 0 | 20.8 | 41.6 | 83.2
| Mean live fetuses/litter | - | −3 | −12 | −18%^*^
| Mean percentage resorptions^e^ | - | 7^*^ | 8^*^ | 10%^*^

Within each category of effect, organized by study confidence then descending publication year. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: NR = not reported; NC = not characterized; T = testosterone; LH = luteinizing hormone; FSH = follicle-stimulating hormone.

a Studies that evaluated male reproductive system toxicity are included in this table. Studies are organized by endpoint, species, and lowest dose tested.

b Response relative to control for mean data, or incidence data.

c ^(^Vosoughi et al., 2012^;^ Vosoughi et al., 2013^)^ reported histopathology and sperm measure data for the same low-exposure group study animals. However, serum LH and FSH data were presented only in Vosoughi et al. (2012) and serum T and testes weight data were presented only in Vosoughi et al. (2013).

d Incidence data not reported.

e Data digitized using Grab It!™, Datatrend Software.

* Statistically significant difference from control value, as reported by the study author.

Study exposure levels converted from ppm to mg/m^3^ are presented in italics (1 ppm = 1.23 mg/m^3^).

##### Summary of Animal Evidence Synthesis Judgments on Developmental and Reproductive Toxicity

###### Developmental Toxicity

The following factors led to the synthesis judgment that the animal studies on developmental toxicity provide indeterminate evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: A few low confidence studies reported decreased fetal survival, altered fetal or postnatal growth, as well as structural anomalies; however, findings were overall inconsistent across studies and no higher confidence studies were available.

###### Female Reproductive Toxicity

The following factors led to the synthesis judgment that the animal studies on developmental toxicity provide indeterminate evidence of formaldehyde exposure-induced effects. A judgment of slight would have been supported if not for the confounding concerns for this nonrespiratory effect.

- Consistency and Study Confidence: Three low confidence studies reported some female reproductive effects; however, no higher confidence studies were available and there was significant concern for confounding in the available studies which examined only very high formaldehyde levels.
- Coherence: Several of the findings in the low confidence studies were biologically coherent, including effects on ovarian weights, histopathology and circulating hormones.

###### Male Reproductive Toxicity

The following factors, in particular the strong consistency and coherence of findings, led to the synthesis judgment that the animal studies on male reproductive toxicity provide robust evidence of formaldehyde exposure-induced effects.

- Consistency and Study Confidence: One high and three medium confidence studies consistently observed multiple manifestations of male reproductive effects in both rats and mice, although effects on male reproductive organ weights across studies were inconsistent.
- Dose-Response: Dose-dependent effects on some endpoints (serum T; histopathology) were observed in two or more high or medium confidence studies.
- Coherence: Findings from high and medium confidence studies indicated a constellation of biologically coherent male reproductive effects, including decreased serum testosterone, testes and epididymal histopathology, and effects on sperm.
- Biological Plausibility: Multiple biomarkers of oxidative stress, as well as heat shock protein induction, have been observed in the testes or epididymides of exposed rats in well-conducted studies. Heat shock protein immunoreactivity and oxidative stress resulting in hypomethylated sperm (no studies were identified that evaluated sperm methylation changes) have been linked to human male infertility.

#### Evidence on Mode of Action

Mode of action (MOA) information for potential developmental and reproductive toxicity associated with formaldehyde exposures is limited. No definitive data have been identified that fully support a specific MOA for developmental outcomes, or for alterations in male or female reproductive system conformation or function. Because it is considered unlikely that formaldehyde is distributed via systemic circulation to the reproductive organs, this section discusses potential mechanisms by which formaldehyde exposures might indirectly affect reproductive outcomes following toxic insult at the portal of entry. Mechanistic events associated with respiratory health effects (see Sections 3.2.1–3.2.4 and Appendix C.7) were considered. Biological mechanisms that could plausibly be associated with developmental and reproductive toxicity are discussed, based upon consideration of experimental animal data that included inhalation exposures to formaldehyde. These include: oxidative stress and neuroendocrine-mediated effects (alterations of adrenergic or gonadotropic hormones). Although additional study is needed to better define and verify these potential mechanisms, they could be operant in several primary outcomes that have been noted across toxicology or epidemiology studies with inhalation exposures to formaldehyde: developmental delays, fetal loss, and effects on sperm quality and quantity.

1) Effects on the reproductive system that are due to indirect oxidative stress, possibly linked to inflammatory responses following formaldehyde exposures (evidence from three medium and two low confidence studies (Zhou et al., 2006; Zhou et al., 2011b; Sapmaz et al., 2018; Ozen et al., 2002; Ozen et al., 2005).

Oxidative stress/damage by reactive oxygen species (ROS) has been hypothesized to play a role in reproductive and developmental toxicity (Wells and Winn, 1996; Juchau et al., 1992; Fantel and Macphail, 1982). Markers of increased oxidative stress have been identified in the blood following formaldehyde inhalation exposures (see Section 3.2.3 and Appendix C.7), and thus, this could also be occurring in peripheral tissues. Plausibly, inflammatory mediators, ROS, or other factors observed in the blood could be operant in reproductive or developmental outcomes by indirectly eliciting responses in the reproductive system or in the developing fetus.

ROS-related outcomes have been detected in cells and tissues distal from the POE, notably in the male reproductive system, where testicular and epididymal toxicity and effects on sperm have been observed. In a medium confidence study in rats, Ozen et al. (2002) investigated the mechanism of oxidative stress associated with testes toxicity by assessing testicular iron, copper, and zinc levels. Zinc and copper levels were reduced in the rat testes, consistent with an increase in testicular ROS. A medium confidence study in rats (Sapmaz et al., 2018) identified a statistically significant decrease in glutathione peroxidase (GSH-Px) activities and a statistically significant increase in malondialdehyde (MDA) levels, A low confidence study (Zhou et al., 2006) investigated biomarkers of oxidative stress as a potential MOA for testicular toxicity following inhalation exposures of rats to formaldehyde. Significant effects on antioxidants and redox enzymes were observed: decreases in superoxide dismutase (SOD), GSH-Px, and glutathione (GSH), as well as an increase in the oxidative stress biomarker, MDA. The authors also demonstrated the protective effect of coadministration with the antioxidant vitamin E (Zhou et al., 2006) on decreased testes weight, biochemical alterations, histopathological effects, or on sperm count, motility, and morphology. Zhou et al. (2011b), another low confidence study from the same research laboratory, demonstrated significantly decreased SOD and GSH-Px activities and significantly increased MDA levels in the epididymides of rats exposed to formaldehyde. No studies have been identified that specifically evaluated the generation of ROS in fetuses following maternal inhalation exposures to formaldehyde, which would be directly informative to this potential relationship.

Chemical or physical stress has been shown to increase the synthesis of heat shock protein 70 (Hsp70), which is involved in protein folding and repair (Craig and Schlesinger, 1985), regulation of apoptosis (Takayama et al., 2003), and it is synthesized during normal spermatogenesis (Dix et al., 1997; Dix, 1997). Additionally, testicular heat shock protein immunoreactivity has been associated with human infertility (Werner et al., 1997). Ozen at al. (2005), a medium confidence study, reported the detection of increased Hsp70 in spermatogenic cells from the seminiferous tubules of rats following 13 weeks of inhalation exposure to formaldehyde. The increase in testicular Hsp70 could reflect a response to chemical (formaldehyde) stress to the respiratory system, but no mechanisms exist to explain this potential association. Regardless, the role of heat shock proteins in mammalian fetal development is well-recognized (Walsh et al., 1997).

It has also been proposed that oxidative stress resulting from formaldehyde exposure could result in epigenetic consequences to the male reproductive system (Duong et al., 2011). Tunc and Tremellen (2009) reported that oxidative stress to sperm DNA has resulted in hypomethylation in infertile men. Abnormal methylation of a key spermatogenic gene is associated with defective sperm (Navarro-Costa et al., 2010). This represents a hypothetical indirect mechanism by which formaldehyde could influence methylation in sperm DNA and alter male fertility. None of the studies reporting sperm alterations or related measures (see previous sections) examined the potential role of sperm methylation in these outcomes.

2) Neuroendocrine-mediated mechanisms: disruption of the hypothalamus-pituitary-adrenal gland (HPA) axis or hypothalamic-pituitary-gonadal (HPG) axis (evidence from two high, two medium, and one low confidence studies—(Vosoughi et al., 2012; Vosoughi et al., 2013; Sorg et al., 2001a; Sari et al., 2004; Ozen et al., 2002; Kitaev et al., 1984).

A stress-induced mechanism might contribute to adverse outcomes on the reproductive system and development in the absence of systemic distribution of formaldehyde.

Disruption of the HPA axis: Stressors such as chemical exposure can cause increased secretion of CRH in the hypothalamus, ACTH in the anterior pituitary gland, and adrenal corticosteroids in the adrenal gland (Smith and Vale, 2006). In support of this hypothesis, a high confidence study, Sorg et al. (2001a), demonstrated an increase in blood corticosterone levels after inhalation exposure to formaldehyde. Additionally, Sari et al. (2004), a medium confidence study, reported effects of inhalation formaldehyde exposures to mice on CRH neurons in the hypothalamus and ACTH cells in the pituitary gland. The effects of stress on disruptions to reproductive function and outcome in humans are well-recognized (Negro-Vilar, 1993; Mcgrady, 1984; Barnea and Tal, 1991). The preoptic area of the hypothalamus is considered a potential site of integration between the HPA axis and gonadal steroid hormones (Smith and Vale, 2006).

Disruption of the HPG axis: A steroidal endocrine-mediated mechanism would be consistent with outcomes observed in some of the reproductive and developmental epidemiology and toxicology studies. Developmental delays can result from effects on the maternal HPG axis. Hormone levels in pups were not measured in any identified studies; however, there are three studies in adult animals that have directly tested for changes in reproductive hormones after formaldehyde exposure. Kitaev et al. (1984), a low confidence study, observed serum FSH increases and LH decreases after inhaled formaldehyde in adult female rats. Alterations in hormone levels could compromise pregnancy maintenance. Another potentially endocrine-mediated outcome, lack of ovarian luteal tissue in females exposed to formaldehyde, was reported in a low confidence study by Maronpot et al. (1986). In males, alteration of the HPG axis by formaldehyde exposure could also be theoretically operant. A high confidence study in mice (Vosoughi et al., 2012; Vosoughi et al., 2013) and a medium confidence study in rats (Ozen et al., 2002), reported significant serum testosterone level decreases, accompanied by histopathological evidence of seminiferous tubule depletion. (Vosoughi et al., 2012; Vosoughi et al., 2013) also reported a significant decrease in serum LH at 24 hours after inhalation formaldehyde exposure. This is notable because the initiation and maintenance of spermatogenesis in rodents and primates require LH stimulation (Plant and Marshall, 2001). Reduced testosterone levels might also contribute to sperm quality and quantity decrements.

These two potential mechanisms are not necessarily mutually exclusive. If verified, they could be shown to be acting alone for certain endpoints (in which case the others may not be operant) or in concert for others. Nevertheless, as stated above, no definitive data have been identified that define an MOA(s) explaining how developmental or reproductive outcomes might occur following inhalation exposure to formaldehyde.

##### Summary of Inferences Regarding Mode of Action

No verified MOA exists for how formaldehyde could elicit reproductive or developmental effects without systemic distribution; however, several lines of evidence exist to support the potential for effects through indirect mechanisms.

#### Evidence Integration Summary

Hazard conclusions integrating the evidence of developmental and reproductive hazards in humans and animals were drawn for two categories: female reproductive or developmental toxicity (TTP, spontaneous abortion, birth outcomes, fetal survival, growth, and malformations), and male reproductive toxicity (see Table 3-60). Specifically, for the purposes of this assessment and based on the outcomes reported in the epidemiological literature, female reproductive toxicity and developmental toxicity were considered as a group because it is difficult to distinguish the underlying events that may have resulted in either a delayed recognized pregnancy or fetal loss.

##### Female reproductive or developmental toxicity

While studies that evaluated physiological measures of reproductive health in females were not available, two medium confidence studies reported strong associations of occupational exposure to formaldehyde with decreased fecundability, increased TTP, and spontaneous abortion (Taskinen et al., 1999; John et al., 1994). A third study also reported an elevated risk of spontaneous abortion with higher exposure frequency of similar magnitude, but the effect estimate may have been biased to an unknown degree by confounding from coexposure to xylene (Taskinen et al., 1994). Excluding the study would not change the weight-of-evidence conclusion for the epidemiological evidence. It is recognized that the decreased fecundability and increased TTP might have resulted from early fetal loss or be a consequence of alterations in maternal reproductive function (discussed below). Only one of the occupational studies (in woodworkers) reported the levels of formaldehyde that resulted in the observed associations (0.27 mg/m^3^) (Taskinen et al., 1999). Studies of hospital, nursing, or medical employees generally did not report an association with formaldehyde exposure, although these low confidence studies tended to use less informative exposure-assessment methods, a major limitation that reduced the sensitivity of these studies. An association of uncharacterized birth defects with maternal exposure (Zhu et al., 2006; Saurel-Cubizolles et al., 1994; Hemminki et al., 1985) was suggested in some occupational epidemiological studies; the precision of the ORs was quite low, as indicated by the wide CIs, which limited the sensitivity of these analyses. Three studies of pregnancy cohorts indicate an association with fetal growth including biparietal diameter in the 2^nd^ trimester and birthweight, although there are questions about the interpretation of the results overall given that stronger associations were observed in a population with very low exposures (Franklin et al., 2019) and a relatively weak association was observed in a population with higher exposure with potential confounding by TVOCs (Chang et al., 2017). Preterm birth and low birth weight were not associated with higher formaldehyde exposure among a cohort of male woodworkers in China (Wang et al., 2012).

Animal studies evaluated several endpoints relevant to developmental toxicity (i.e., decreased survival, decreased growth, or increased evidence of structural anomalies) or female reproductive toxicity (i.e., ovarian and uterine pathology, ovarian weight, or hormonal changes). All available studies were of low confidence, primarily due to exposure-quality concerns (i.e., the use of formalin, or an uncharacterized test substance). In addition, there was considerable heterogeneity in both of these data sets, and consistent evidence supporting manifestations of toxicity after formaldehyde exposure was not reported. However, as several of these studies did identify potential findings of concern, these outcomes are deserving of additional study. In addition, several studies examining effects on the nervous system after formaldehyde exposure in rats during development suggest that formaldehyde inhalation might have the potential to affect the developing nervous system (see Section 3.3.1), however, additional studies are needed to clarify these preliminary findings. Studies on developmental immunotoxicity were considered not informative (see Section 3.2.3 and Appendix B.3.4) and no epidemiological studies of children were identified.

Overall, the evidence indicates that inhalation of formaldehyde likely causes increased risk of developmental or female reproductive toxicity in humans, given sufficient exposure conditions. This conclusion is based on moderate evidence in observational studies finding increases in TTP and spontaneous abortion risk among women occupationally exposed to formaldehyde; the evidence in animals is indeterminate, and a plausible, experimentally verified MOA explaining such effects without systemic distribution of formaldehyde is lacking. The primary basis for this conclusion is from studies of women with occupational exposures to formaldehyde.

##### Male reproductive toxicity

Few epidemiological studies evaluated effects on the male reproductive system. Two studies of male woodworkers in China from one research group reported associations with lower total and progressive sperm motility, and delayed fertility and spontaneous abortion (Wang et al., 2012; Wang et al., 2015). The investigators used a well-designed exposure assessment to evaluate associations in this highly exposed occupational population (0.22–2.91 mg/m^3^). Two other studies with low sensitivity to detect associations (due to concerns with low precision and exposure misclassification) did not observe effects on sperm counts and morphology or spontaneous abortion among exposed men (Ward et al., 1984; Lindbohm et al., 1991).

Animal studies were available that evaluated several effects from formaldehyde inhalation exposure on the male reproductive system. A coherent set of high and medium confidence studies in mice and rats that tested formaldehyde exposures >6 mg/m^3^ reported effects on multiple endpoints, although interpretations could not be drawn regarding the potential for these effects in experimental animals at lower formaldehyde exposure levels. Qualitative and quantitative histopathological effects were observed in the testes and epididymides of a high confidence study in mice (Vosoughi et al., 2012; Vosoughi et al., 2013) and in two medium confidence rat studies (Sarsilmaz et al., 1999; Ozen et al., 2005). Histopathological findings in testes were also observed by (Sapmaz et al., 2018), a medium confidence study in rats. These observations were supported by similar findings in a number of low confidence studies. Decreased serum testosterone (T) was also observed in one high and one medium confidence studies in mice and rats, respectively (Vosoughi et al., 2012; Vosoughi et al., 2013; Ozen et al., 2005), as well as in a low confidence rat study (Zhou et al., 2011b). The decreased serum T is biologically consistent with testicular Leydig cell damage observed in the histopathological evaluations reported in well-conducted studies (Vosoughi et al., 2012; Vosoughi et al., 2013; Sarsilmaz et al., 1999). Downstream effects of disruptions in spermatogenesis observed in the histopathology data included decreased sperm count and motility, and increased sperm morphological abnormalities in a high confidence study in mice (Vosoughi et al., 2012; Vosoughi et al., 2013) and several low confidence studies in rats. Testes and epididymides weight alterations are often correlated to some degree with histopathology in those organs; however, while significantly decreased dose- and duration-dependent testes weights were observed in the medium confidence study in rats by Ozen et al. (2002), organ weight alterations were not observed in the high confidence study in mice by (Vosoughi et al., 2012; Vosoughi et al., 2013), were equivocal in the other medium confidence study in rats by Sarsilmaz et al. (1999), and results in low confidence studies were mixed, preventing clear interpretations.

Overall, the evidence indicates that inhalation of formaldehyde likely causes increased risk of reproductive toxicity in men, given sufficient exposure conditions, based on robust evidence in animals that presents a coherent array of adverse effects in two species, and slight evidence from observational studies of occupational formaldehyde exposure. No plausible, experimentally verified MOA exists to explain such effects without systemic distribution of formaldehyde; however, some support for indirect effects in rodents is provided by relevant mechanistic changes in male reproductive organs. The primary basis for this conclusion is based on bioassays in rodents testing formaldehyde concentrations above 6 mg/m^3^ (no medium or high confidence studies tested lower exposure levels).

##### Data gaps

While reduced fecundity observed in exposed women may be due to reproductive toxicity or toxicity to the developing fetus, no studies are available in exposed humans or animal experiments that provide more complete assessments of reproductive organ endpoints. This also is true for the evaluation of postnatal developmental toxicity. The anthropomorphic findings by a single study of low residential exposures are concerning and additional studies are needed of these endpoints. The findings by Wang et al. (2015) suggesting formaldehyde-related toxicity to sperm and possible resulting effects on fecundity and fetal survival, and which may be supported by a low confidence study in mice (Xing et al., 2007a), provide evidence of male-mediated decreases in fetal viability, and should be investigated further. Ideally, such investigations would include additional human studies of different populations using similarly detailed exposure assessments, as well as single or multigeneration reproductive toxicity studies in animals (which were not identified in the current database). Such studies would also assess female reproductive outcomes, which are not extensively evaluated in the current database. Ideally, any future toxicology experiments would generate formaldehyde exposures using paraformaldehyde to eliminate the uncertainties pertaining to potential confounding by methanol that limit the majority of currently available animal studies on developmental and reproductive toxicity.

Importantly, as the hazard conclusion for male reproductive toxicity is based on animal studies that only tested formaldehyde exposures ≥6 mg/m^3^ (one study) or ≥12 mg/m^3^, which introduces uncertainties regarding potential irritation-related effects (e.g., reflex bradypnea, which is not experienced by humans and is expected to be operant at these levels; see Appendix C.2), well-conducted, detailed animal studies testing these endpoints at lower formaldehyde concentrations are warranted.

Table 3-60 Evidence integration summary for effects of formaldehyde inhalation on female reproductive or developmental toxicity

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Female Reproductive or Developmental Toxicity
Human (female reproductive or developmental toxicity) | Consistency and Study Confidence | - Two medium confidence studies in two independent populations (woodworkers, cosmetologists): decreased fecundability and increased spontaneous abortion risk. Supporting evidence of association with spontaneous abortion from one low confidence study among laboratory workers.; - Two medium confidence studies of pregnancy cohorts indicating decreased birth weight and head circumference. Two low confidence studies report small increased risk of malformations. | - Null evidence on fecundability and spontaneous abortion from five low confidence studies with low sensitivity [note: this does not substantially decrease certainty in the findings from the medium confidence studies]. | Moderate Based on consistent observations among medium confidence studies, risk estimates of strong magnitude and observed dose dependence. | The evidence indicates that inhalation of formaldehyde likely causes increased risk of female reproductive or developmental toxicity in humans, given sufficient exposure conditions.^a^; Primarily based on studies of women with occupational exposures to formaldehyde.; Potential susceptibilities: no specific data were available to inform potential differences in susceptibility.
Human (female reproductive or developmental toxicity) | Strength and Precision | - Risk estimates of large magnitude were observed in the highest exposure groups for time-to-pregnancy and spontaneous abortion | - Increases in the two low confidence studies of malformations were small and imprecise. | Moderate Based on consistent observations among medium confidence studies, risk estimates of strong magnitude and observed dose dependence.
Human (female reproductive or developmental toxicity) | Dose-Response | - The medium confidence studies of fecundability and spontaneous abortion evaluated multiple exposure categories with highest risk at highest exposure level. | | Moderate Based on consistent observations among medium confidence studies, risk estimates of strong magnitude and observed dose dependence.
Human (female reproductive or developmental toxicity) | Coherence | N/A | | Moderate Based on consistent observations among medium confidence studies, risk estimates of strong magnitude and observed dose dependence.
Human (female reproductive or developmental toxicity) | Biological Plausibility | No direct evidence. However, evidence of elevated oxidative stress in the blood of exposed adults (see Section 3.2.3 and Appendix C.7) might provide a potential indirect linkage. This was not interpreted as sufficient to notably increase certainty.
Animal (developmental toxicity) | Consistency and Study Confidence | - Findings from some low confidence studies included decreased fetal survival (pre- or postimplantation loss), altered fetal or postnatal growth, and structural anomalies. | - Findings were overall inconsistent (mixed) across studies on these outcomes. Variations in study design and reporting deficiencies inhibit interpretation.; - All studies are low confidence, with significant concern for confounding. | Indeterminate for developmental toxicity Based on inconsistent findings for several developmental endpoints from low confidence studies. [Note: developmental neurotoxicity (slight evidence in animals) is addressed under nervous system effects (Section 3.3.1) and did not influence this synthesis judgment].
Animal (developmental toxicity) | Strength and Precision | N/A
Animal (developmental toxicity) | Dose-Response | N/A
Animal (developmental toxicity) | Coherence | N/A
Animal (developmental toxicity) | Biological Plausibility | No direct evidence. However, evidence of elevated oxidative stress and hormonal alterations in the blood of adult rodents (see Section 3.2.3 and Appendix C.7) might provide a potential indirect linkage, as it is recognized that both oxidative stress and the HPG axis have potential roles in developmental toxicity. This was not interpreted as sufficient to increase certainty to a level beyond indeterminate.
Animal (female reproductive toxicity) | Consistency and Study Confidence | - Three low confidence studies (two in rats, one in mice) observed some effects on the female reproductive system. | - All studies are low confidence, with significant concern for confounding (particularly given the very high formaldehyde levels tested and the nonrespiratory outcome) across the small evidence base. | Indeterminate (near to Slight) for female reproductive toxicity Based on findings of reproductive toxicity in a few low confidence studies.
Animal (female reproductive toxicity) | Strength and Precision | N/A | | Indeterminate (near to Slight) for female reproductive toxicity Based on findings of reproductive toxicity in a few low confidence studies.
Animal (female reproductive toxicity) | Dose-Response | N/A | | Indeterminate (near to Slight) for female reproductive toxicity Based on findings of reproductive toxicity in a few low confidence studies.
Animal (female reproductive toxicity) | Coherence | - Although findings are sparse, the observed decreased ovarian weight is coherent with some of the histopathology (e.g., hypoplasia).; - Some of the observed hormonal changes in rats could reflect ovarian toxicity, although this linkage was not specifically tested. | | Indeterminate (near to Slight) for female reproductive toxicity Based on findings of reproductive toxicity in a few low confidence studies.
Animal (female reproductive toxicity) | Biological Plausibility | Neuroendocrine-mediated mechanisms, particularly involving disruption of the hypothalamic-pituitary-gonadal axis, are consistent with alterations of female reproductive hormones observed in low confidence rodent studies following formaldehyde exposures. This was not interpreted as sufficient to increase certainty to a level beyond indeterminate. | | Indeterminate (near to Slight) for female reproductive toxicity Based on findings of reproductive toxicity in a few low confidence studies.
Other inferences | - Relevance to humans: Relevant health effects observed in humans are the primary basis for the hazard determination. Most of the animal studies only tested high levels of formaldehyde expected to cause irritant effects that may not occur in humans.; - MOA: No experimentally established MOA exists, and any potential mechanisms have not been well studied.

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

Table 3-61 Evidence integration summary for effects of formaldehyde inhalation on male reproductive toxicity

Evidence | Factor | Increasing certainty | Decreasing certainty | Synthesis judgment | Hazard determination
Male Reproductive Toxicity
Human | Consistency and Study Confidence | - Two medium confidence studies of exposure among male woodworkers observed an inverse association with sperm motility measures, as well as an increased prevalence of time to pregnancy, spontaneous abortion, and birth defects. | - The two medium confidence studies were conducted by the same research group and are presumed to involve overlapping populations (note: certainty was not reduced by null evidence for effects on sperm counts and morphology in two low confidence studies). | Slight; Based on deficits in sperm motility, fecundity, spontaneous abortion and birth defects in a male occupational population. | The evidence indicates that inhalation of formaldehyde likely causes increased risk of reproductive toxicity in men, given sufficient exposure conditions.^a^; Primarily based on bioassays in rats and mice testing formaldehyde concentrations above 6 mg/m^3^(no medium or high confidence studies tested lower exposure levels).; Potential susceptibilities: No specific data were available to inform potential differences in susceptibility.
Human | Strength and Precision | N/A | | Slight; Based on deficits in sperm motility, fecundity, spontaneous abortion and birth defects in a male occupational population.
Human | Dose-Response | N/A | | Slight; Based on deficits in sperm motility, fecundity, spontaneous abortion and birth defects in a male occupational population.
Human | Coherence | | - Some biologically related endpoints (e.g., sperm counts) were unchanged, although adequate power was a concern. | Slight; Based on deficits in sperm motility, fecundity, spontaneous abortion and birth defects in a male occupational population.
Human | Biological Plausibility | No directly relevant studies were identified. | | Slight; Based on deficits in sperm motility, fecundity, spontaneous abortion and birth defects in a male occupational population.
Animal | Consistency and Study Confidence | - Histopathological lesions of the testes or epididymides in one high confidence study in mice, three medium confidence studies in rats, and five low confidence studies in rats.; - One high confidence study in mice and four low confidence studies in rats: dose-related effects on epididymal sperm.; - One high confidence study in mice, one medium confidence study in rats, and one low confidence study in rats: dose-related decreased serum testosterone (and decreased serum luteinizing hormone in the high confidence study in mice).; - One low confidence study in mice with evidence of male-mediated decreases in fetal survival. | - Mixed results for organ weight changes (i.e., testes; epididymis) across studies.; - Null evidence for testes histopathology in one low confidence study in mice did not reduce certainty. | Robust; Based on coherent changes to the male reproductive system in a high confidence study of mice and three medium confidence studies of rats at formaldehyde levels above 6 mg/m^3^ (lower levels were not tested in wellconducted studies).; [Note: No multigeneration study was conducted].
Animal | Strength and Precision | N/A
Animal | Dose-Response | - Dose-related qualitative or quantitative histopathological lesions of the testes or epididymides in the available medium and high confidence studies.
Animal | Coherence | - Multiple high or medium confidence studies provided coherent evidence of toxicity spanning biochemical, cellular, tissue, and functional levels.
Animal | Biological Plausibility | - Multiple biomarkers of oxidative stress, as well as heat shock protein induction, have been observed in the testes or epididymides of exposed rats in well-conducted studies. Heat shock protein immunoreactivity and oxidative stress resulting in hypomethylated sperm (no studies were identified that evaluated sperm methylation changes) have been linked to human male infertility.
Other inferences | - Relevance to humans: Some uncertainty regarding the relevance of the animal evidence exists, as the studies only tested extremely high concentrations expected to cause strong irritant effects that may not occur in humans; however, in light of the concordant findings in a well-conducted study of humans and an absence of other evidence to the contrary, the relevance of animal male reproductive toxicity outcomes to humans is presumed.; - MOA: No experimentally established MOA exists, and any potential mechanisms have not been well-studied; however, mechanistic data provide some support for indirect effects on the male reproductive system.

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn.

a The “sufficient exposure conditions” are more fully evaluated and defined through dose-response analysis in Section 5.1.

### 3.3.3 Lymphohematopoietic Cancers

The specific endpoints considered in this section include diagnoses of Hodgkin lymphoma, multiple myeloma, myeloid leukemia, or lymphatic leukemia in exposed humans (note: diagnosis of non-Hodgkin lymphoma, a nonspecific grouping of dozens of different lymphomas, was not formally evaluated; see Appendix B.3.9), as well as experimental animal and mechanistic studies relevant to the interpretation of potential effects on the lymphohematopoietic (LHP) system.

Human studies provided robust evidence for myeloid leukemia and slight evidence for multiple myeloma based on epidemiology studies of occupational formaldehyde levels either in specific work settings (e.g., cohort studies) or in case-control studies. Aneuploidy in chromosomes 1, 5, and 7 in circulating myeloid progenitor cells, considered a potential primary target for LHP carcinogenesis, was associated with occupational formaldehyde exposure. The type of aneuploidies observed in the formaldehyde-exposed asymptomatic human workers are also found in patients with leukemia, as well as in other worker cohorts at increased risk of developing leukemias, which provides support for the plausibility of an association between chronic formaldehyde exposure and leukemogenesis. Moreover, the strong and consistent evidence from a large set of studies that observed mutagenicity in circulating leukocytes of formaldehyde-exposed humans, specifically chromosomal aberrations (CA), and micronucleus (MN) formation, provides additional evidence of biological plausibility for these cancer types. Further support is provided by studies that observed perturbations to immune cell populations in peripheral blood associated with formaldehyde exposure. In particular, decreases in red blood cells (RBCs), white blood cells (WBCs), and platelets, along with a 20% decrease in colony-forming units that arose in vitro as descendants from dedicated progenitors of granulocytes and macrophages (CFU-GMs) were observed in the same exposed group, suggesting both a decrease in the circulating numbers of mature RBCs and WBCs as well as possible decreases in the replicative capacity of myeloblasts.

Increased LHP cancers have not been observed in a well-reported chronic rodent bioassay involving inhalation exposure of both rats and mice to formaldehyde, nor in another rat bioassay that failed to report the incidence of non-nasal neoplastic lesions. Further, positive associations with leukemia have not been reported in rodent studies. Thus, there appears to be a lack of concordance between evidence from chronic rodent bioassays and human epidemiological evidence, although such concordance is not necessarily expected (U.S. EPA, 2005a).

Taken together, based on the robust human evidence for these cancers from studies that reported increased risk in groups exposed to occupational formaldehyde levels, the evidence demonstrates that formaldehyde inhalation causes myeloid leukemia in humans. Separately, based on a limited number of epidemiological studies and potentially relevant mechanistic evidence in exposed humans, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma and Hodgkin lymphoma. While mechanisms for the induction of myeloid leukemia are yet to be elucidated, they do not appear to require direct interactions between formaldehyde and bone marrow constituents, and either are different in animals or the existing animal models tested thus far do not characterize the complex process leading to cancers in exposed humans.

#### Overview of Lymphohematopoietic Cancer Biology

LHP neoplasias describe a broad group of cancers of the blood, bone marrow, and lymph nodes, which includes leukemia, lymphoma, and myeloma. The various LHPs originate through a multistep process in different stages of the hematopoietic pathway (the process through which blood cells are formed). In normal human adults, this process occurs primarily in the bone marrow, with the exception of lymphocytes, which continue to mature in the thymus, spleen, and peripheral tissues. Therefore, LHPs may derive from discrete precursor or stem cells, as well as mature lymphoid cells. Figure 3-35 illustrates the hematopoietic pathway, the location of each differentiation (bone marrow or peripheral tissues), and the likely site of occurrence for transformation in each subtype of LHP. Briefly, normal hematopoietic stem cells differentiate into one of two lineages: myeloid or lymphoid progenitor cells. Normal myeloid progenitor cells may then differentiate into mature RBCs, platelets, or granulocytes; lymphoid progenitor cells derive T and B lymphocytes as well as natural killer (NK) cells and dendritic cells (see Figure 3-35).

LHP neoplasias arise from abnormal hematopoietic and lymphoid cells that are unable to differentiate normally to form mature blood cells. Neoplasias following the myeloid lineage are designated as chronic or acute leukemias, depending on the rate of expansion and the dominant stage of cell differentiation. Acute leukemias are characterized by a rapid onset, whereas chronic leukemias develop slower and progress over a period of months or years. Lymphoid neoplasias may either reside in the blood as chronic or acute lymphoblastic leukemias or develop within peripheral lymphoid sites such as the lymph nodes, spleen, or thymus—these are designated as lymphomas. Some rare leukemias exhibit both myeloid and lymphoid characteristics and are known as biphenotypic leukemias (Russell, 1997).

The majority of leukemias originate in the bone marrow at the hematopoietic stem cell stage or at a later, lineage-restricted stage. Specifically, adult leukemias of myeloid origin such as acute myeloid leukemia (AML), myelodysplastic syndrome (MDS), and chronic myeloid leukemia (CML) as well as adult acute lymphoblastic leukemia (ALL) are thought to originate at the stem or progenitor cell stage (Warner et al., 2004).

Lymphomas primarily derive from mature lymphoid cells in peripheral tissues such as the spleen, lymph nodes, and thymus, and are generally classified as either Hodgkin or non-Hodgkin lymphomas (NHLs) depending on the appearance of a specific cancer cell type found in Hodgkin lymphomas. Within the larger groupings of NHLs are numerous subtypes with unique characteristics and origins. Myeloma (also called multiple myeloma) is a cancer of the plasma cells that forms a mass or tumor located in the bone marrow. Most lymphomas and all myelomas, as well as some rare leukemias/lymphomas (adult T cell leukemia [TCL], adult chronic lymphocytic leukemia [CLL], prolymphocytic leukemia [PLL], and hairy cell leukemia [HCL]) originate in mature lymphoid cells (Harris et al., 2001; Greaves, 1999).

While hematopoietic stem cells are normally located in the bone marrow, they do spontaneously mobilize into the peripheral blood at low levels, or in response to chemical insult, mobilize in large numbers (Schulz et al., 2009; Lévesque et al., 2007). These mobilized cells remain in circulation for very short periods of time (minutes to hours) and then localize to peripheral tissues or in some cases, return to the bone marrow. Consequently, there may be a recirculation of hematopoietic stem cells between the bone marrow and other peripheral tissues. Therefore, the potential exists for DNA damage or other types of leukemogenic alteration during this mobilization between tissues. Cells confined to the bone marrow are less vulnerable to environmental insult than cells that enter the general circulation. Therefore, knowledge of the location of origin of discrete LHPs is important to understanding the potential targets of carcinogenic compounds.

Figure 3-35 The hematopoietic pathway and likely sites of neoplastic transformation for LHPs

Abbreviations: AML = acute myeloid leukemia; CML = chronic myeloid leukemia; MDS = myelodysplastic syndrome; ALL = acute lymphoblastic leukemia; NHL = non-Hodgkin lymphoma; HL = Hodgkin lymphoma; MM = multiple myeloma; TCL = T cell lymphoma; CLL = chronic lymphocytic leukemia; PLL = prolymphocytic leukemia; HCL = hairy cell leukemia (adapted from: https://www.seattlecca.org/diseases/chronic-myeloid-leukemia-cml/cml-facts-0).

#### Lymphohematopoietic Cancers in Human Studies

Each specific type of LHP cancer (myeloid leukemia, lymphatic leukemia, multiple myeloma, and Hodgkin lymphoma) is reviewed and evaluated independently in the sections below. For each type of LHP cancer, the evidence is organized by considerations that inform the strength of evidence (e.g., consistency, exposure-response) and evaluation of the potential for bias and insensitivity in individual studies to affect the estimates of relative risk (RR). Evidence tables for each type of LHP cancer (Tables 3-63 through 3-66) are included that are organized first by the study evaluation conclusions (i.e., high, medium, low) and then by publication year.

##### Myeloid leukemia

###### Epidemiological evidence

The most specific classification of myeloid leukemia diagnosis that is commonly reported across the epidemiological literature has been based on the first three digits of the Eighth or Ninth Revision of the ICD code (i.e., myeloid leukemia ICD-8/9: 205) —although the smaller sets of studies that reported specific results for AML (ICD-8/9: 205.0) and CML (ICD-8/9: 205.1) are discussed. For the purposes of this evaluation, cancer cases reported as monocytic leukemia or nonlymphocytic leukemia were included as myeloid leukemia. Evidence describing the association between formaldehyde exposure and the risk of myeloid leukemia was available from 13 epidemiological papers reporting on 10 different study populations—three case-control studies (Talibov et al., 2014; Hauptmann et al., 2009; Blair et al., 2001) and ten cohort studies (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Saberi Hosnijeh et al., 2013; Pira et al., 2014; Ott et al., 1989; Meyers et al., 2013; Hayes et al., 1990; Coggon et al., 2014; Beane Freeman et al., 2009). Hauptmann et al. (2009) combined the study populations from Hayes et al. (1990) with those from Walrath and Fraumeni (Walrath and Fraumeni, 1983, 1984) and reconstructed individual exposure estimates. Checkoway et al. (2015) reanalyzed Beane Freeman et al. (2009) with a different definition of the exposure categories and presented results for specific subtypes of myeloid leukemia. These are the only formaldehyde studies that specifically evaluated the risk of myeloid leukemia. Details of the reported results of high, medium, and low confidence are provided in the evidence table for myeloid leukemia (see Table 3-63) following the causal evaluation.

###### Consistency of the observed association

The majority of studies of the 10 populations reported elevated risks of myeloid leukemia (or a specific subtype) associated with exposure to formaldehyde for at least one metric of exposure, although four low confidence studies reported results based on fewer than 10 cases and two other low confidence studies reported relative effect estimates of RR = 1.02 and OR = 1.17. These studies examined different populations, in different locations^36^ and exposure settings, and using different study designs. The study results presented in Table 3-63 (by confidence level and publication date) detail all of the reported associations between exposures to formaldehyde and the risks of developing or dying from myeloid leukemia along with a summary graphic of any limitation and the confidence classification of the available effect estimates. Results for all studies are plotted in Figure 3-36 and grouped by the exposure-assessment methodology (e.g., population-level versus individual-level) and by the type of occupation of the exposed workers (e.g., anatomist/embalmers, industrial workers, garment workers). The same results for the high and medium confidence studies are plotted in Figure 3-37, and exposure-response trends describing the effect estimates of association between formaldehyde exposure and risk of myeloid leukemia in high confidence studies are shown in Table 3-62.

The first five studies in Figure 3-36 (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Pira et al., 2014; Hayes et al., 1990) shown at the left, under the header “Population-level exposure assessment” followed the health of a group of workers exposed to formaldehyde in a plastics manufacturing facility and four sets of anatomists and embalmers—professions known to be exposed to formaldehyde. These studies compared the risk of death from myeloid leukemia among those workers to the risk of death from myeloid leukemia among the general population. All five studies showed elevated RRs of myeloid leukemia mortality as measured by the mortality ratios, including two studies with 95% CIs that excluded the null, thereby decreasing the likelihood of chance as an alternative explanation for these findings. One study (Stroup et al., 1986) observed a much higher RR (standardized mortality ratio [SMR] 8.8) compared with the others (SMR ∼1.4 to 2.0); this higher estimate was based on one subtype (CML), and was relatively imprecise (95% CI: 1.8, 22.5). The results from Pira et al. (2014) and Stroup et al. (1986) were classified with low confidence. The results from the other three studies (Walrath and Fraumeni, 1983, 1984; Hayes et al., 1990) were classified with medium confidence and are shown in Figure 3-36 to document their findings while acknowledging that these three studies populations were combined in (Hauptmann et al., 2009).

The second set of eight studies (Talibov et al., 2014; Saberi Hosnijeh et al., 2013; Ott et al., 1989; Meyers et al., 2013; Hauptmann et al., 2009; Coggon et al., 2014; Blair et al., 2001; Beane Freeman et al., 2009) is displayed in Figure 3-36 beneath the header of “Individual-level exposure assessment.” A general strength of this second set of eight studies was their use of individualized exposure data, which, for six of the studies, allowed for the evaluation of exposure-response relationships with increased formaldehyde exposures using multiple metrics of exposure; additional detail of this consideration is included below under the exposure-response relationships section below. A further strength is that three of these studies had their effect estimates classified with high confidence (Meyers et al., 2013; Hauptmann et al., 2009; Beane Freeman et al., 2009) and were able to evaluate the impact of the timing of initial exposure relative to mortality; further detail of this consideration is included below under the temporal relationship section below. One study’s results that were classified with medium confidence due to exposure measurement error (Coggon et al., 2014) showed a slightly elevated risk for those workers with the highest job exposures, but also slightly decreased risk for those with the highest duration of exposure. The results from the other four studies with individual-level exposure assessment were classified with low confidence due to the lower quality exposure assessment methods (Talibov et al., 2014; Saberi Hosnijeh et al., 2013; Ott et al., 1989; Blair et al., 2001). Additional findings from each of the studies are provided in Table 3-63. Different measures of exposure reflected different risks and this was true within studies and across studies but all provided some evidence of increased risk of dying from myeloid leukemia associated with formaldehyde exposure. One study showed the strongest relationship of myeloid leukemia mortality with duration of formaldehyde exposure (Hauptmann et al., 2009). Another showed increased risks for peak exposure and average exposure but not for cumulative exposure or “any” exposure (Beane Freeman et al., 2009). The Checkoway et al. (2015) reanalysis of Beane Freeman et al. (2009) reported nonsignificant increased risks of AML and CML after redefining the referent group to include all workers with peak exposures of less than 2 ppm as well as some originally classified as having peak exposures of greater than 4 ppm because those worker’s peak exposures were thought to be either too frequent or too rare. The result of this change in exposure assessment shifted nine cases of myeloid leukemia from the highest exposure category to the lowest exposure category (Checkoway et al., 2015).^37^ Because this change in methodology for exposure assessment blends the highly exposed people with the low and unexposed people and thereby induces bias toward the null reducing study sensitivity, these results were classified with low confidence. A third study showed increased risk in the study population as a whole that was stronger among workers with the longest duration of exposure and workers with the greatest length of time since first occupational exposure to formaldehyde (Meyers et al., 2013).

The pattern of increased risk of myeloid leukemia (ICD-8/9: ‘204’) associated with exposure to formaldehyde reflects the associations seen within two subtypes, AML and CML. Among the studies with separate estimates by subtype, risks were elevated for both AML and CML, with the associations for CML appearing to be as strong as or stronger than the associations with AML. Four studies reported specific results for CML (Stroup et al., 1986; Saberi Hosnijeh et al., 2013; Checkoway et al., 2015; Blair et al., 2001). All four studies reported elevated risks of CML. Six studies reported specific results for AML; two were classified with high confidence (Meyers et al., 2013; Hauptmann et al., 2009), and four with low confidence (Talibov et al., 2014; Saberi Hosnijeh et al., 2013; Checkoway et al., 2015; Blair et al., 2001). Both of the high confidence results showed nonsignificantly elevated risks of AML associated with formaldehyde, as did three of four of the low confidence results—although substantially higher risks were reported in the high confidence results. One low confidence result showed a slight decrease in risk of AML (Blair et al., 2001). Results specific to AML are plotted in Figure 3-38. Four of these six studies reported effect estimates for both ML and AML (Saberi Hosnijeh et al., 2013; Meyers et al., 2013; Hauptmann et al., 2009; Checkoway et al., 2015) on a total of 14 specific metrics of exposure. To assess whether the results for AML were comparable to those for ML, the pair-wise effect estimates were evaluated.^38^ The correlation between the AML results and the ML results was 0.72 (p < 0.0001) and the slope was 0.97 indicating a very strong alignment among these studies and strongly suggesting that the collective results for the broader group of ML cases may be inferred to represent AML as well.

###### Strength of the observed association

While reported relative effect estimates were consistently elevated above the null value of one across the 10 study populations, the magnitude of the relative effect estimates varied with the quality of the exposure assessment. Studies with higher quality exposure data based on individual-level exposure assessment generally reported higher relative effect estimates (stronger associations). The Hauptmann (2009) study reported the strongest association based on 34 cases of myeloid leukemia of whom 33 had ever performed an embalming (OR = 11.2, 95% CI 1.3, 95.6; p = .027); however, with just 1 case subject who had never embalmed in the reference group, the effect estimate, while statistically significant, is imprecise. The investigators conducted additional analyses that defined the reference group as having performed fewer than 500 embalmings so as to include five cases of myeloid leukemia in the reference group and those results are discussed below.

The results at the highest levels of formaldehyde exposure showed an approximately two- to three-fold relative increase in risk of mortality from myeloid leukemia (Meyers et al., 2013; Hauptmann et al., 2009; Blair et al., 2001; Beane Freeman et al., 2009) with one exception, which reported no increase in risk among those who had ever had a job in the highest category of exposure (Coggon et al., 2014). This may have been due to the choice in (Coggon et al., 2014) to classify as highly exposed all workers who ever worked in a highly exposed job, even if just for one year out of 20, a methodology that mixes workers with many years of high exposure together with workers with just a single year of high exposure, thereby potentially diluting the strength of the association. Results from other studies using a cruder exposure classification (i.e., exposed versus not exposed), and low to medium confidence, generally showed elevated risks in the 1.02– to 2–fold range (Talibov et al., 2014; Saberi Hosnijeh et al., 2013; Pira et al., 2014; Ott et al., 1989). Results from the studies with higher quality exposure data were judged with greater confidence.

###### Temporal relationship of the observed association

Two related aspects of time are encompassed in the consideration of temporality. One aspect is the necessity for the exposure to precede the onset of the disease. In each of the studies, the formaldehyde exposures among the study participants started prior to their diagnoses of myeloid leukemia or deaths from myeloid leukemia and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and was done in a blinded fashion with respect to outcome status. The second aspect involves the time course of formaldehyde exposures in relation to the incidence of myeloid leukemia and death from myeloid leukemia; this aspect of time is defined as the etiologically relevant window of time when exposure to a causal factor is relevant to the causation of disease. From the epidemiological literature of benzene-related leukemia, it is known that there can be an induction/latency period for some environmental agents and that the induction period may exceed 10 years (Rinsky et al., 1987). The epidemiological literature for formaldehyde and myeloid leukemia describes three studies that evaluated the impact of the TSFE (Meyers et al., 2013; Hauptmann et al., 2009; Beane Freeman et al., 2009). All three studies show some indication of an increase in risk at about 15–20 years of time since first exposure (TSFE) to formaldehyde that is consistent with a biologically relevant induction/latency period. However, the Hauptmann et al. (2009) study clearly shows increased risk at 20+ years of time since first exposure. (Beane Freeman et al., 2009) reported that the best fitting exposure lag length of time to potentially account for cancer latency was 18 years. While those three studies support the estimation of the beginning of the potentially relevant window of time, the window may also have an ending when exposures that have occurred a very long time before may no longer be relevant to the causation of disease.

In the mortality follow-up of this cohort through 1980, the High peak exposure had RR = 3.92 (95% CI 0.78, 19.67; p-trend = 0.12) (Blair et al., 1986); in the follow-up through 1994, the High peak exposure had RR = 2.79 (95% CI 1.08, 7.21; p-trend = 0.02) (Hauptmann et al., 2003); and in the follow-up through 2004 the RR = 1.78 (95% CI 0.87, 3.64; p-trend = 0.07). Beane Freeman (2009) reported the effect estimates for follow-up through every individual calendar year starting with 1965 and ending with 2004. Figure 1 of (Beane Freeman et al., 2009) shows the association between peak formaldehyde exposure and the risk of myeloid leukemia; risks of High exposures were compared against the lowest exposed category. Risks were significantly elevated in each year of follow-up during the 1990’s before losing significance in the 2000’s. Such a pattern may reflect the closing of the potentially relevant window of time when exposures are relevant to disease causation. With very long follow-up of a cohort, those workers who were highly exposed may have experienced a window of increased risks of myeloid leukemia associated with exposure to formaldehyde that tapered off or closed. This phenomenon may occur as additional background cases of myeloid leukemia − unrelated to formaldehyde exposure, were added to both the High and the Low exposures groups thereby bringing the relative risks of these groups toward the null value of 1.00.

As formaldehyde exposure had ceased by 1980 for all but 3.5% of person-time and latency analyses showed higher risks in the period 15 to 25 years after first exposure with the best fitting exposure lag of 18 years (Beane Freeman et al., 2009), the 1994 follow-up of the NCI formaldehyde cohort (Hauptmann et al., 2003) which reported that High peak exposure had RR = 2.79 (95% CI 1.08, 7.21; p-trend = 0.02) may be a more informative estimate of the association between formaldehyde exposure and risks of myeloid leukemia. There is some indication that a similar phenomenon may have occurred in the study of garment worker and the mortality follow-up through 1988 (Pinkerton et al., 2004) which reports somewhat stronger results for workers with 20+ years TSFE than was reported in the 2008 follow-up (Meyers et al., 2013)(SMR = 1.91; p < 0.05 vs. SMR = 1.49 (95% CI 0.90, 2.32); and for duration longer than 10 years (SMR = 2.19 vs. SMR =1.84). If the follow-up of these two cohorts has exceeded the window of time when exposures are relevant to disease causation, then the evidence may be somewhat stronger than is evident in the reports from the most recent follow-ups.

###### Exposure-response relationship

Of the studies that provided evidence to evaluate the association between exposure to formaldehyde and the risk of myeloid leukemia, four studies (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Hayes et al., 1990) followed the health of anatomists and embalmers and did not have specific individual-level exposure data to assess an exposure-response relationship. One study (Ott et al., 1989) did assess individual-level exposures but did not report differentiated risks by exposure levels of formaldehyde. One study, Saberi Hosnijeh et al. (2013), which had risk analyses on three levels of exposure for other health endpoints, did not identify any people with high exposures to formaldehyde and thus could only compare risks of low exposures with risks of no exposures.

The remaining studies did present distinct risk estimates differentiated by formaldehyde exposure levels. Meyers et al. (2013) reported results by workers’ year of first exposure, their time since first occupational exposure, and by their duration of exposure. Data on cumulative exposure was not available. The investigators considered that the initial study years (prior to 1963) had the highest formaldehyde exposures as ongoing industrial hygiene practices were thought to have decreased exposures over time. For first employment in the earliest period (before 1963), the overall SMR was 1.37 (95% CI 0.75, 2.30) while first employment in the middle (1963−1970) and late time periods (after 1970) had ORs of 1.13 and 1.15. There was an extensive investigation of exposure-response by duration of exposure with external and internal comparisons by strata of duration as well as multivariate Poisson modeling of exposure duration, all of which showed increasing risk with longer duration (see Table 3-63). Multiple models all showed positive trends of increasing rate ratios with increasing exposure duration (see Figure 1B in (Meyers et al., 2013)), but the continuous model with duration was not statistically significant with rate ratio of 1.04 per one year increase in duration (95% CI 0.097, 1.12); (Meyers et al., 2013), for durations between 6.5 and 16 years, the rate ratio was 0.43 (95% CI 0.06, 2.39), for durations between 16 and 19 years, the rate ratio was 6.42 (95% CI 1.40, 32.2) and for durations greater than 19 years the rate ratio was 1.71 (95% CI 0.25, 11.0). The evidence from (Meyers et al., 2013) provides only modest evidence of an exposure-response relationship based on duration of exposure.

Beane Freeman et al. (2009) evaluated results by each worker’s highest formaldehyde concentration during a “peak” exposure event, by average intensity of exposure, by cumulative exposure, and by duration of exposure. “Peak” exposure events were defined as short-term exposures (<15 minutes) that exceed the TWA formaldehyde intensity (Beane Freeman et al., 2009). Workers’ “peak” exposures were defined as the highest concentration among their “peak” exposure events. Among only those workers with some “peak” exposure, the RR in the highest category compared to the lowest category was 1.78 (95% CI 0.87, 3.64) with a trend p-value of 0.13 for the continuous values of the peak exposure data. While the investigators considered the lowest group of exposed workers to be the most appropriate reference group (possibly due to a potential for selection bias between exposed and unexposed workers), had the unexposed group been used as the referent group, the RR would have been higher (~ RR of 2.17). This relationship between myeloid leukemia and high peak formaldehyde exposure is not only seen for the complete 2004 follow-up when the average length of follow-up was 42 years, but throughout the cohort experience ((Beane Freeman et al., 2009), see Figure 1 in the publication). These plots show that during the 1970s and 1980s, the RR > 10 until about 1970 and then remained elevated between RR = 4 and RR = 6 until about 1980 and then between about RR = 2 and RR = 3 through the end of follow-up in 2004. Such a consistent finding of a strong effect over many years of follow-up reduces the possibility that the results for the full follow-up period could be due to chance. Beane Freeman et al. (2009) reported that among all workers there was an exposure-response trend through follow-up in 2004 with p-value of 0.07 for the continuous values of the peak exposure data; and there was an exposure-response trend through follow-up in 1994 with p-value of 0.0087.

Beane Freeman et al. (2009) also reported that among those with any formaldehyde exposure in the 2004 follow-up, the RR in the highest category of average intensity of exposure was 1.61 (95% CI 0.76, 3.39) with little evidence of any trend for the continuous exposure data at nearly 40 years of follow-up (p = 0.40). However, the supplementary tables from Beane Freeman et al. (2009) reported that for follow-up through 1994, the exposure-response trend value for all workers was p = 0.11. No trend in RR was found for cumulative exposure (see Table 1-60). Overall, the evidence from Beane Freeman et al. (2009) provides limited evidence of an exposure-response relationship based on “peak” exposures.

Hauptmann et al. (2009) evaluated results by multiple metrics of exposure including exposure duration, number of embalmings, cumulative exposure, average formaldehyde intensity while embalming, time-weighted formaldehyde intensity, and peak exposure. Peak exposure levels were defined as the maximum of moving averages of any series of measurements covering 15 minutes. Results for two different reference groups were reported, the first set from the authors’ Table 3 used unexposed people as the “a priori” reference group but as there was only one case of myeloid leukemia in this group, the results were statistically unstable with wide Cis. Those results showed an OR of 13.6 (95% CI 1.6, 119.7) for the highest category of duration with a statistically significant trend p-value of 0.020; and an OR of 9.5 (95% CI 1.1, 86.0) for the highest category of average exposure; and an OR of 13.0 (95% CI 1.4, 116.9) for the highest category of peak exposure. The second set of results redefined the reference category as those people with fewer than 500 lifetime embalmings. Thus, this referent group includes some exposed individuals, which mutes the categorical comparisons (i.e., this methodology causes bias toward the null and underestimates the effect estimates) but allows for more statistically stable effect estimates as there were five cases of myeloid leukemia in this reference group. Those results showed an OR of 3.9 (95% CI 1.2, 12.5) for the highest category of exposure duration, an OR of 2.3 (95% CI 0.7, 7.5) for the highest category of average exposure, and an OR of 2.9 (95% CI 0.9, 9.5) for the highest category of peak exposure.

Hauptmann et al. (2009) assessed two methodologies to measure potential exposure-response trends: (1) trends based on the complete range of continuous exposure metric data and (2) trends based on the ordinal levels of the categories of the difference exposure metrics, with the former method selected a priori. There was a statistically significant positive exposure-response trend for duration of formaldehyde exposure (p = 0.020) as well as a statistically significant positive trend for peak exposures (p = 0.036) and the trend p-value for average formaldehyde exposure was 0.058. For the other metrics of exposure, the continuous exposure metric data trend p-values were greater than 0.10. However, analyses using the ordinal levels of the exposure metrics also showed trends for the TWA8 intensity (p = 0.021), the number of embalmings (p = 0.012) and for cumulative exposure (p = 0.023). Table 3-62 provides a summary of the exposure-response trends reported by Hauptmann et al. (2009), Beane Freeman et al. (2009), and Meyers et al. (2013)—all three of which reported results that were judged to be of high confidence (see Table 3-63 and Appendix B.3.9).

Table 3-62 Summary high confidence studies of reported exposure-response trends describing the effect estimates of association between formaldehyde exposure and risk of myeloid leukemia

High confidence studies reporting exposure-response trend assessments
| Hauptmann et al. (2009) ^a^ | | Beane Freeman et al. (2009) ^a^ | | Meyers et al. (2013) ^a^
Exposure metric | Continuous | Categorical | Continuous 2004 follow-up | Continuous 1994 follow-up | Continuous | Categorical
Duration | p = 0.020 | NR | NR | NR | p = 0.30 | NR
# of Embalmings | p = 0.314 | p = 0.012 | NR | NR | NR | NR
Cumulative | p = 0.192 | p = 0.023 | p = 0.44 | p = 0.171 | NR | NR
Average | p = 0.058 | NR | p = 0.40 | p = 0.110 | NR | NR
TWA8 | p = 0.396 | p = 0.021 | NR | NR | NR | NR
Peak | p = 0.036 | NR | p = 0.07 | p = 0.0087 | NR | NR

Abbreviations: TWA8 = 8-hour time-weighted average; NR = not reported.

a Formaldehyde exposure measured as a continuous variable among unexposed and exposed persons.

Coggon et al. (2014) classified workers’ exposures according to the highest level of exposure ever experienced, which can be interpreted as an indicator of peak occupational exposure because each worker was assigned the highest exposure classification ever experienced, and reported exposure-level specific results with an OR of 1.10 (95% CI 0.51, 2.38) for workers with peak occupational exposure of low/moderate and an OR of 1.26 (95% CI 0.39, 4.08) for those workers who had ever worked in a job with high exposures. Among the group with high exposures, those with less than one year of employment at high exposure had an OR of 1.77 (95% CI 0.45, 7.03; 9 exposed cases) while those with 1 year or more at high exposure had an OR of 0.96 (95: CI: 0.24, 3.82; 4 exposed cases). The limitation of this study was the likelihood of nondifferential exposure misclassification due to the quality of the exposure assessment and the lack of any latency analysis. The expected impact is of a downward bias toward the null thereby muting any potential exposure-response. The evidence from Coggon et al. (2014), while potentially biased toward the null and statistically unstable within the “high” exposure category (nine exposed cases), provided only weak evidence of an exposure-response relationship with “peak exposure.”

Blair et al. (2001) reported separate results for AML and CML by low and high intensity of exposure although data were only available to examine exposure-response for CML. Blair et al. (2001) reported an OR = 1.3 (95% CI 0.6, 3.1) for low exposure based on seven cases and an OR = 2.9 (95% CI 0.3, 24.5) for high exposure based on one case. Given that that the OR in the high exposure group was based on only one case, these results provided only weak evidence of an exposure-response relationship.

Talibov et al. (2014) reported results across three levels of cumulative formaldehyde exposure and showed some increasing risk with each increasing level of exposure from HR = 0.89 (95% CI: 0.81, 0.97) in the lowest group to HR = 0.92 (95% CI: 0.83, 1.03) in the middle group and HR = 1.17 (95% CI: 0.91, 1.51) in the highest exposure group. The test for trend showing an exposure-response had a p-value of 0.07. As with the other results classified with low confidence, the limitation of this study was the likelihood of nondifferential exposure misclassification due to the quality of the exposure assessment, which was based on decennial census records. The expected impact is of a downward bias toward the null thereby muting any potential exposure-response.

The evidence for an exposure-response relationship is most strongly supported by the study of embalmers by Hauptmann et al. (2009), which reported statistically significant trends for five of the six exposure metrics evaluated including duration of exposure, the number of embalmings, cumulative exposure, average intensity of exposure, TWA8 exposure, and “peak” exposure; and a borderline significant trend for the sixth exposure metric (average intensity of exposure). Beane Freeman et al. (2009) reported a borderline significant exposure-response trend for the measure of “peak” exposure that was shown to be statistically significant over the course of more than 30 years of annual follow-up but which faded somewhat as the maturity of the cohort approached 40 years of follow-up—a span of time that far exceeds the latency of all but a few cancers such as mesothelioma. Meyers et al. (2013) also provided solid evidence of an exposure-response relationship based on duration of exposure. Coggon et al. (2014), a medium confidence study, found little evidence for an exposure-response relationship.

While it is not known which of these exposure metrics is of greatest biological relevance for myeloid leukemia, all of the exposure metrics reflect different aspects of increased exposure to formaldehyde and associations with increased risks of myeloid leukemia. As the different measures of exposure are all likely to be correlated with each other, it may not be possible at this time to single out one exposure metric as more biologically meaningful than another. It appears that these various trend results reflect some true underlying exposure-response relationship.

Observations of exposure-response relationships are strong evidence in support of an association consistent with causation (Hill, 1965) and against a spurious association because it would necessitate a third (uncontrolled) factor, which changes in the same manner (direction and magnitude) as the exposure of interest (CDC, 2004) to explain away each of the reported exposure-response relationships.

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias is an unlikely alternative explanation for the consistent evidence of increased risk of myeloid leukemia in people exposed to formaldehyde. Selection bias is unlikely in the case-control studies of myeloid leukemia as the case-control (Blair et al., 2001) and nested case-control studies (Hauptmann et al., 2009; Coggon et al., 2014) evaluated exposure status without regard to outcome status and had participation levels of 77-99%. Each of the cohort studies (Walrath and Fraumeni, 1983, 1984; Talibov et al., 2014; Stroup et al., 1986; Saberi Hosnijeh et al., 2013; Pira et al., 2014; Ott et al., 1989; Meyers et al., 2013; Hayes et al., 1990; Coggon et al., 2014; Beane Freeman et al., 2009) included at least 75% of eligible participants and lost fewer than 3% of participants over the course of mortality follow-up.

Selection bias due to the comparison of a generally healthier group of workers to those in the general population (called the healthy worker effect) could have obscured a truly larger effect of formaldehyde exposure in analyses based on “external” comparisons with mortality in the general population in one study with an SMR = 0.64 for “all cancers” (Stroup et al., 1986), but would not influence analyses using “internal” or matched comparison groups (Meyers et al., 2013; Hauptmann et al., 2009; Coggon et al., 2014; Blair et al., 2001; Beane Freeman et al., 2009). The clearest example of the potential influence of the healthy worker effect is shown in the comparison on results from the study of garment workers (Meyers et al., 2013). That study compared SMRs using an external referent group based on the general population alongside standardized rate ratios (SRR) using an internal referent group of workers in the lowest category of duration of exposure. Compared to the general population (matched on sex, race, age, and calendar time), garment workers with less than a 3-year duration of exposure had an SMR of 0.65 (95% CI 0.18,1.65), which is a 35% lower risk of dying from myeloid leukemia than people in the general population. For workers with a 3- to 9-year duration, the SMR was 1.46, and for workers with 10 or more years of exposure, the SMR was 1.84. Internal comparisons were made by comparing the risk of dying from myeloid leukemia in workers with 3–9 years of exposure to the risk among those with less than 3 years of exposure for an SRR of 2.12. The SRR for workers with 10 or more years of exposure was 3.25. Selection bias may explain why results based on comparisons of mortality of workers with the general population are lower than comparisons of workers to workers. Selection bias does not explain increased risks in exposed workers.

Information bias is an unlikely alternative explanation for the consistent evidence of increased risk of myeloid leukemia in people exposed to formaldehyde. Information bias may distort epidemiological findings when subjects’ true exposures are inaccurately assigned at the individual or group level. A differential misclassification, in which exposure status influences disease classification by the investigator (or disease status influences exposure classification), can lead to spurious (i.e., “false positive”) associations. However, information bias is considered unlikely among these studies of myeloid leukemia mortality because the likelihood of differential misclassification based on these study designs is low. The assignment of exposure status or calculation of exposure measures in the cohort studies was done independent of knowledge of the cause of death. In the nested case-control studies by Coggon et al. (2014) and Hauptmann et al. (2009) the ascertainment of individual-level exposure levels was independent of the cause of death. In the case-control study by Blair et al. (2001), many different occupational exposures were evaluated based on interview data and subjects were unlikely to be aware of specific chemical exposure of interest in the study. Therefore, an exposure-related recall bias of their occupational histories is unlikely. The exposure assignments in Blair et al. (2001) were based on typical exposure characteristics of the individual’s job and were made blinded to case/control status.

There does not appear to be any evidence of confounding that would provide an alternative explanation for the observed association of formaldehyde exposure with increased risk of myeloid leukemia seen in these studies. Chemicals and other coexposures that have not been independently associated with myeloid leukemia are not expected to confound results. However, other known risk factors for myeloid leukemia include exposure to benzene, ionizing radiation, and smoking. Benzene is not used in the embalming process (Stewart et al., 1992; Hayes et al., 1990) and was not a chemical coexposure in the garment plants (Stayner et al., 1985), and consequently, could not be a confounder of those results. Benzene was evaluated by Ott et al. (1989) and not found to be a risk factor (OR = 1.0), and thus, could not be a confounder. Benzene was specifically assessed as a potential confounder among the U.S. industrial workers (Beane Freeman et al., 2009) and found not to be a confounder. Ionizing radiation can be a coexposure for embalmers but the limited extent of such radiation exposure is unlikely to explain the observed association in embalmers (Hauptmann et al., 2009). Exposures to ionizing radiation were not mentioned as coexposures for the industrial workers or the garment workers, and would not be expected to be correlated with their formaldehyde exposures. Smoking was controlled for in the analyses of the embalmers (Hauptmann et al., 2009), which demonstrated a statistically significant exposure-response relation between both duration of formaldehyde exposure and peak exposures with increased risk of death from myeloid leukemia. Blair et al. (2001) also controlled for smoking in their analyses thereby reducing the likelihood of confounding by smoking. Smoking was not evaluated as a potential confounder in the industrial or garment worker cohorts (Meyers et al., 2013; Coggon et al., 2014; Beane Freeman et al., 2009). However, there is no evidence that smoking rates in the industrial or garment worker cohorts (Meyers et al., 2013; Beane Freeman et al., 2009) were correlated with formaldehyde exposures—a necessary condition for potential confounding. Moreover, the internal comparisons used in the analyses of the industrial cohort should mitigate any potential confounding effects of smoking because smoking rates within a cohort are likely to be more similar than compared to the general population.

Consistency across multiple studies is demonstrated by a pattern of increased risk in different populations, exposure scenarios, and time periods. Such consistency makes unmeasured confounding an unlikely alternative explanation for the observed associations. This consistency also reduces the likelihood of chance as an alternative explanation. The observations of exposure-response trends similarly reduce the likelihood that chance, confounding, or other biases can explain the observed association.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Consistent increases in risk observed across a set of high and medium confidence results from epidemiology studies of occupational formaldehyde levels using varied study designs and populations.
- Strength and Precision: The higher confidence results at the highest levels of formaldehyde exposure showed an approximately 2- to 3-fold relative increase in risk of mortality from myeloid leukemia with one exception. Results from studies using cruder exposure classifications generally showed elevated risks in the 1.02– to 2–fold range.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from myeloid leukemia, allowing time for cancer induction, latency, and mortality.
- Dose-Response: Reported exposure-response relationships showed that increased exposure to formaldehyde were associated with increased risk of dying from myeloid leukemia.

###### Causal evaluation

The human evidence synthesis judgments strongly support a causal conclusion and are further supported by a judgment of reasonable confidence that alternative explanations are ruled out, including chance, bias, and confounding within individual studies or across studies. Consistent observations of genotoxicity in peripheral blood lymphocytes across several occupational studies involving diverse exposure settings further supports the evidence in humans, as does evidence of perturbations to immune cell populations in peripheral blood with formaldehyde exposure.

###### Conclusion

- The available epidemiological studies provide robust evidence of an association consistent with causation between formaldehyde exposure and increased risk of myeloid leukemia.

Figure 3-36 Epidemiological studies reporting myeloid leukemia risk estimates

Results specifically for acute myeloid leukemia (AML) or chronic myeloid leukemia (CML) are noted by these abbreviations. Details of the reported results of high, medium, and low confidence are provided in the evidence table for myeloid leukemia (see Table 3-63). SMR = standardized mortality ratio; PMR = proportionate mortality ratio; RR = relative risk; OR = odds ratio. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 3]). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure. *The dotted line extending from Hauptmann et al. (2009) reflects that study’s inclusion of the original cohorts from Walrath and Fraumeni (Walrath and Fraumeni, 1983, 1984) and Hayes et al. (1990), which were combined with extended follow-up in Hauptmann et al. (2009) in a nested case-control study with internal referents.

Figure 3-37 High and medium confidence epidemiological studies reporting myeloid leukemia risk estimates

For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 14]). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure. Abbreviations: OR = odds ratio; RR = relative risk; SMR = standardized mortality ratio; HR = hazard ratio.

Figure 3-38 Epidemiological studies reporting acute myeloid leukemia risk estimates

For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 8]). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure. Abbreviations: OR = odds ratio; RR = relative risk; SMR = standardized mortality ratio; HR = hazard ratio.

Table 3-63 Epidemiological studies of formaldehyde exposure and risk of myeloid leukemia

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Beane Freeman et al. (2009) with supplemental online tables.; Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the U.S., followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine UCOD from myeloid leukemia (ICD-8: 205).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists who took 2,000 air samples from representative jobs, and monitoring data from 1960 through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01–4.3).; Median cumulative exposure = 0.6 ppm-years (range 0–107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from before 1946 through 1980. Median length of follow-up: 42 years. Duration and timing since first exposure were evaluated.; Variation in exposure:; For all variations in exposure:; Level 1 (unexposed); Peak exposure:; Level 2 (>0 to <2.0 ppm); Level 3 (2.0 to <4.0 ppm); Level 4 (≥4.0 ppm); Average intensity:; Level 2 (>0 to <0.5 ppm); Level 3 (0.5 to <1.0 ppm); Level 4 (≥1.0 ppm); Cumulative exposure:; Level 2 (>0 to <1.5 ppm-years); Level 3 (1.5 to <5.5 ppm-years); Level 4 (≥5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders and found not be confounders.; [[underlined: As noted in] Appendix B.3.9[underlined: :] There was no information on smoking; however, according to Blair et al. (1986), “The lack of a consistent elevation for tobacco-related causes of death, however, suggests that the smoking habits among this cohort did not differ substantially from those of the general population.”; Beane Freeman et al. (2013) reported that among a sample of 379 cohort members, they “found no differences in prevalence of smoking by level of formaldehyde exposure.”] | Internal comparisons:; [underlined: Peak exposure:]; 1980 follow-up:; Highest peak RR = 3.92 (0.78–19.67); (p-trend = 0.12); 1994 follow-up:; Highest peak RR = 2.79 (1.08–7.21); (p-trend = 0.02); 2004 follow-up:; Level 1 RR = 0.82 (0.25-2.67) [4]; Level 2 RR = 1.00 (Ref. value) [14]; Level 3 RR = 1.30 (0.58–2.92) [11]; Level 4 RR = 1.78 (0.87–3.64) [19]; p-trend (exposed) = 0.13;; p-trend (all) = 0.07; [underlined: Average intensity:]; Level 1 RR = 0.70 (0.23–2.16) [4]; Level 2 RR = 1.00 (Ref. value) [24]; Level 3 RR = 1.21 (0.56–2.62) [9]; Level 4 RR = 1.61 (0.76–3.39) [11]; p-trend (exposed) = 0.43;; p-trend (all) = 0.40; [underlined: Cumulative exposure:]; Level 1 RR = 0.61 (0.20–1.91) [4]; Level 2 RR = 1.00 (Ref. value) [26]; Level 3 RR = 0.82 (0.36–1.83) [8]; Level 4 RR = 1.02 (0.48–2.16) [10]; p-trend (exposed) > 0.50;; p-trend (all) = 0.44; [underlined: Duration of exposure:]; No evidence of association (data not shown).; [underlined: Time since first exposure:]; >0–15 years RR = 1.00 (Ref. value) [3]; >15–25 years RR = 2.44 (0.45–13.25) [11]; >25–35 years RR = 0.77 (0.11–5.24) [8]; >35 years RR = 0.67 (0.09–4.88) [24]; External comparisons:; SMR_Unexposed_ = 0.65 (0.25–1.74) [4]; SMR_Exposed_ = 0.90 (0.67–1.21) [44]
Reference: Beane Freeman et al. (2009) as re-analyzed by Checkoway et al. (2015) with differences noted.; Population: No differences.; Outcome definition: Death certificates used to determine UCOD from acute and chronic myeloid leukemia (ICD-8: 205.0 and 205.1).; Design: No differences.; Analysis: HRs estimated using Cox proportional hazards models controlling for age, sex, and race; adjusted for pay category compared to workers in the redefined lowest exposed category. Did not control for calendar year as did Beane Freeman et al. (2009). Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); Checkoway et al. (2015) [reviewed here]; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null) | Exposure assessment: No differences in measurements; however, the exposure metrics we redefined.; Redefined peak exposures as having “at least one continuous month of employment in jobs identified in the original exposure characterization as likely having short-term exposure excursions of 2 ppm or more to less than 4 ppm or 4 ppm or more on a weekly or daily basis.”; Redefinition of peak exposures excluded “employment in jobs likely experiencing (1) short-term excursions more than 0 ppm and less than 2 ppm; (2) short-term excursions identified as occurring as frequently as hourly; and (3) short-term excursions identified as occurring as infrequently as monthly.”; Duration and timing: No differences.; Variation in exposure:; For all variations in exposure:; Peak exposure:; Level 1 (exposed to <2.0 ppm); Level 2 (2.0 to <4.0 ppm); Level 3 (≥4.0 ppm); Average intensity:; Did not evaluate; Cumulative exposure:; Level 1 (exposed to <0.5 ppm-years); Level 2 (>0.5 to <2.5 ppm-years); Level 3 (≥2.5 to <5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders by Beane Freeman et al. (2009) and found not be confounders. Checkoway et al. (2015) did not re-evaluate potential confounding. | Internal comparisons:; Myeloid Leukemia; [underlined: Peak exposure:]; Level 1 HR=1.00 (Ref. value) [27]; Level 2 HR=2.09 (1.03–4.26) [11]; Level 3 HR=1.80 (0.85–3.79) [10]; p-trend = 0.06; [underlined: Cumulative exposure:]; Level 1 HR=1.00 (Ref. value) [23]; Level 2 HR=0.98 (0.47–2.03) [11]; Level 3 HR=0.94 (0.47–1.86) [14]; p-trend = 0.90; AML; [underlined: Peak exposure:]; Level 1 HR=1.00 (Ref. value) [21]; Level 2 HR=1.71 (0.72–4.07) [7]; Level 3 HR=1.43 (0.56–3.63) [6]; p-trend = 0.31; [underlined: Cumulative exposure:]; Level 1 HR=1.00 (Ref. value) [17]; Level 2 HR=0.87 (0.36–2.12) [7]; Level 3 HR=0.96 (0.43–2.16) [10]; p-trend = 0.90; CML; [underlined: Peak exposure:]; Level 1 HR=1.00 (Ref. value) [6]; Level 2 HR=2.62 (0.64–10.66) [3]; Level 3 HR=3.07 (0.83–11.40) [4]; p-trend = 0.07; [underlined: Cumulative exposure:]; Level 1 HR=1.00 (Ref. value) [6]; Level 2 HR=0.97 (0.24–3.93) [3]; Level 3 HR=0.92 (0.25–3.36) [4]; p-trend = 0.90
Reference: Hauptmann et al. (2009); Population: 6,808 embalmers and funeral directors who died during 1960−1986. Identified from registries of the National Funeral Directors’ Association, licensing boards and state funeral directors’ associations, NY State Bureau of Funeral Directors, and CA Funeral Directors and Embalmers. Deaths were identified from the National Death Index. Next of kin interviews conducted for 96% of cases and 94% of controls.; Outcome definition: Death certificates used to determine UCOD from myeloid leukemia (ICD-8: 205).; Design: Nested case-control study within a prospective cohort mortality study using two internal comparison groups; the first composed of those who had never embalmed (1 case and 55 controls) and the second composed of those who had fewer than 500 embalmings (five cases and 83 controls).; Analysis: ORs calculated using unconditional logistic regression adjusted for date of birth, age at death, sex, data source, and smoking. Lagged exposures were evaluated to account for cancer latency. These results are shown in table 3 of Hauptmann et al. (2009).; Results from the second internal comparison group with <500 embalmings were selected to increase statistical stability. These results are shown in table 4 of Hauptmann et al. (2009); Related studies:; Hayes et al. (1990); Walrath and Fraumeni (1983); Walrath and Fraumeni (1984); Note: The original cohorts from these three original studies were combined in Hauptmann et al. (2009) and follow-up was extended so the case-series overlap and are not independent. However, the three original cohorts used external reference groups for comparison while Hauptmann et al. (2009) selected internal controls, which were independent of the reference groups used in the original studies.; [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Occupational history obtained by interviews with next of kin and coworkers using detailed questionnaires. Exposure was assessed by linking questionnaire responses to an exposure assessment experiment providing measured exposure data. Exposure levels (peak, intensity, and cumulative) were assigned to each individual using a predictive model based on the exposure data. The model explained 74% of the observed variability in exposure measurements.; Multiple exposure metrics including duration (mean = 33.1 years in cases), # of embalming, peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1932 through 1986. Duration of exposure was evaluated. Duration is also a surrogate for time because first exposure since dates of death was closely related to cessation of workplace exposures.; Variation in exposure:; For variations in exposure from table 3 of the publication:; Level 1 (no exposure to embalming); For variations in exposure from table 4 of the publication:; Level 1 (<500 embalming); Duration of exposure:; Level 2 (<20 years); Level 3 (20–34 years); Level 4 (>34 years); Number of embalming:; Level 2 (500–1,422); Level 3 (1,423–3,068); Level 4 (>3,068); Cumulative exposure:; Level 2 (≤4,058 ppm-hrs); Level 3 (4,059−9,253 ppm-hrs); Level 4 (≥9253 ppm-hrs); Average intensity (while embalming):; Level 2 (≤1.4 ppm); Level 3 (>1.4–1.9 ppm); Level 4 (>1.9 ppm); TWA8 formaldehyde intensity:; Level 2 (≤0.10 ppm); Level 3 (>0.10–0.18 ppm); Level 4 (>0.18 ppm); Peak exposure:; Level 2 (<7.0 ppm); Level 3 (7.0 to <9.3 ppm); Level 4 (>9.3 ppm); Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | Internal comparisons (from table 3 in the paper):; Never embalming: OR = 1.00 (Ref. value) [1]; Ever embalming: OR = 11.2 (1.3–95.6) [33]; [underlined: Duration of exposure:]; Level 1 OR = 1.00 (Ref. value) [1]; Level 2 OR = 5.0 (0.5–51.6) [6]; Level 3 OR = 12.9 (1.4–117.1) [13]; Level 4 OR = 13.6 (1.6–119.7) [14]; [underlined: Number of embalming:]; Level 1 OR = 1.0 (Ref. value) [1]; Level 2 OR = 7.6 (0.8–73.5) [7]; Level 3 OR = 12.7 (1.4–116.7) [12]; Level 4 OR = 12.7 (1.4–112.8) [14]; [underlined: Cumulative exposure:]; Level 1 OR = 1.0 (Ref. value) [1]; Level 2 OR = 10.2 (1.1–95.6) [9]; Level 3 OR = 9.4 (1.0–85.7) [10]; Level 4 OR = 13.2 (1.5–115.4) [14]; [underlined: Average intensity (while embalming):]; Level 1 OR = 1.0 (Ref. value) [1]; Level 2 OR = 11.1 (1.2–106.3) [10]; Level 3 OR = 14.8 (1.6–136.9) [13]; Level 4 OR = 9.5 (1.1–86.0) [10]; [underlined: TWA8 formaldehyde intensity:]; Level 1 OR = 1.0 (Ref. value) [1]; Level 2 OR = 8.4 (0.8–79.3) [8]; Level 3 OR = 13.6 (1.5–125.8) [13]; Level 4 OR = 12.0 (1.3–107.4) [12]; [underlined: Peak exposure:]; Level 1 OR = 1.0 (Ref. value) [1]; Level 2 OR = 15.2 (1.6–141.6) [12]; Level 3 OR = 8.0 (0.9–74.0) [9]; Level 4 OR = 13.0 (1.4–116.9) [12]; Internal comparisons (from table 4):; [underlined: Duration of exposure:]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 0.5 (0.1–2.9) [2]; Level 3 OR = 3.2 (1.0–10.1) [13]; Level 4 OR = 3.9 (1.2–12.5) [14]; [underlined: Number of embalming:]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 1.2 (0.3–5.5) [3]; Level 3 OR = 2.9 (0.9–9.1) [12]; Level 4 OR = 3.0 (1.0–9.2) [14]; [underlined: Cumulative exposure:]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 2.1 (0.5–8.1) [5]; Level 3 OR = 2.2 (0.7–7.1) [10]; Level 4 OR = 3.1 (1.0–9.6) [14]; [underlined: Average intensity (while embalming):]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 2.6 (0.8–8.7) [10]; Level 3 OR = 2.8 (0.8–9.1) [10]; Level 4 OR = 2.3 (0.7–7.5) [9]; [underlined: TWA8 formaldehyde intensity:]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 2.4 (0.7–8.2) [8]; Level 3 OR = 2.6 (0.8–8.7) [10]; Level 4 OR = 2.6 (0.8–8.3) [11]; Internal comparisons (from table 4):; [underlined: Peak exposure:]; Level 1 OR = 1.0 (Ref. value) [5]; Level 2 OR = 2.9 (0.9–9.8) [9]; Level 3 OR = 2.0 (0.6–6.6) [9]; Level 4 OR = 2.9 (0.9–9.5) [11]; [underlined: Additional:] [underlined: Acute ML (ICD-8: 205.0)]; Internal comparisons (from table 4):; [underlined: Duration of exposure:]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 OR = 0.4 (0.04–4.9) [1]; Level 3 OR = 2.9 (0.7–12.2) [8]; Level 4 OR = 3.1 (0.7–13.7) [8]; [underlined: Number of embalming:]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 no cases; Level 3 OR = 2.9 (0.7–12.0) [8]; Level 4 OR = 2.9 (0.7–11.6) [9]; [underlined: Cumulative exposure:]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 OR = 1.3 (0.2–9.4) [2]; Level 3 OR = 1.9 (0.4–8.2) [6]; Level 4 OR = 3.2 (0.8–13.1) [9]; [underlined: Average intensity (while embalming):]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 OR = 2.5 (0.6–10.9) [6]; Level 3 OR = 2.0 (0.4–9.4) [5]; Level 4 OR = 2.3 (0.5–10.3) [6]; [underlined: TWA8 formaldehyde intensity:]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 OR = 1.4 (0.3–7.8) [3]; Level 3 OR = 2.6 (0.6–11.4) [7]; Level 4 OR = 2.6 (0.6–11.3) [7]; [underlined: Peak exposure:]; Level 1 OR = 1.0 (Ref. value) [3]; Level 2 OR = 1.8 (0.4–9.3) [4]; Level 3 OR = 2.1 (0.5–9.2) [5]; Level 4 OR = 2.9 (0.7–12.5) [7]
Reference: Meyers et al. (2013); Population: 11,043 workers in three U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion.; Outcome definition: Death certificates used to determine both the UCOD from myeloid leukemia (ICD code in use at time of death).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates. SRRs calculated using LTAS.NET. Rate ratios calculated using Poisson regression analysis based on internal referents.; Related studies:; Stayner et al. (1985); Stayner et al. (1988); Pinkerton et al. (2004); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984 with 12–73 within each department. Formaldehyde levels across all departments and facilities were similar. Geometric TWA8 exposures ranged from 0.09-0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 through 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were evaluated.; Variation in exposure:; Duration of exposure:; Level 1 (<3 years); Level 2 (3–9 years); Level 3 (10 + years); Time since first exposure:; Level 1 (<10 years); Level 2 (10–19 years); Level 3 (20 + years); Duration of exposure (Poisson modeling–lagged 2 years):; Level 1 (<1.6 years); Level 2 (1.6 to <6.5 years); Level 3 (6.5 to <16 years); Level 4 (16 to <19 years); Level 5 (19 + years); Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:; SMR = 1.28 (0.79–1.96) [21]; Within-study external comparisons:; [underlined: Duration of exposure:]; Level 1 SMR = 0.65 (0.18–1.65) [4]; Level 2 SMR = 1.46 (0.59–3.02) [7]; Level 3 SMR = 1.84 (0.88–3.28) [10]; [underlined: TSFE:]; Level 1 SMR = 0.90 (0.02–4.99) [1]; Level 2 SMR = 0.40 (0.01–2.21) [1]; Level 3 SMR = 1.49 (0.90–2.32) [19]; [underlined: Year of first exposure:]; <1963 SMR = 1.37 (0.75–2.30) [14]; 1963-1970 SMR = 1.13 (0.37–2.63) [5]; 1971 + SMR = 1.15 (0.14–4.17) [2]; Internal comparisons:; [underlined: Duration of exposure:]; Level 1 SRR = 1.00 (Ref. value) [4]; Level 2 SRR = 2.12 (0.57-7.85) [7]; Level 3 SRR = 3.25 (0.84–12.63) [10]; [underlined: Duration of exposure] (Poisson modeling–lagged 2 years) [# of cases not given]:; Level 1 rate ratio = 1.00 (Ref. value); Level 2 rate ratio = 1.38 (0.39–5.51); Level 3 rate ratio = 0.43 (0.06–2.39); Level 4 rate ratio = 6.42 (1.40–32.2); Level 5 rate ratio = 1.71 (0.25–11.0); Additional:; [underlined: Acute myeloid leukemia (ICD: 205.0)]; SMR = 1.22 (0.67–2.05) [14]; [underlined: Chronic myeloid leukemia (ICD: 205.1)]; SMR = 1.35 (0.44–3.15) [5]; [underlined: Acute myeloid leukemia (ICD: 205.0)]; [underlined: Internal comparisons:]; [underlined: Duration of exposure:]; Level 1 SMR = 0.46 (0.06–1.68) [2]; Level 2 SMR = 1.52 (0.49–3.56) [5]; Level 3 SMR = 1.81 (0.73–3.73) [7]; [underlined: Time since first exposure:]; Level 1 SMR = 0 (0.00–6.66) [0]; Level 2 SMR = 0 (0.00–2.32) [0]; Level 3 SMR = 1.50 (0.82–2.52) [14]; [underlined: Year of first exposure:]; <1963 SMR = 1.55 (0.77–2.77) [11]; 1963-1970 SMR = 0.64 (0.08–2.30) [2]; 1971 + SMR = 0.83 (0.02–4.60) [1]
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories which produced formaldehyde. Cohort mortality followed from 1941 through 2012. Cause of deaths was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete and only 1.1% lost to follow-up through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from myeloid leukemia (ICD-9: 205).; Design: Cohort mortality study with external comparison group with a nested case-control study.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association.; (Potential bias toward the null↓); IB: Exposure is Group B; lack of latency analysis | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941−1982. Duration was evaluated as more, or less, than one year only among the high exposure group. Timing since first exposure was not evaluated.; Variation in exposure:; Highest exposure level attained; Level 1 (Background); Level 2 (low/moderate); Level 3 (High); Duration of “High” exposures; Level 1 (Background); Level 2 (<1 year); Level 3 (1 year or more); Coexposures: Not evaluated as potential confounders. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium; explanation for underlining:; [As noted in Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers.; [underlined: Asbestos] is associated with URT cancers, but not with LHP cancers.; Other coexposures are not known risk factors for this outcome.; Authors stated that the extent of coexposures was expected to be low.; Potential for confounding may be mitigated by low coexposures.] | External comparisons:; SMR = 1.20 (0.84-1.66) [36]; Within-study external comparisons:; [underlined: Highest exposure level attained]; Level 1 SMR = 1.16 (0.60-2.02) [12]; Level 2 SMR = 1.46 (0.84-2.38) [16]; Level 3 SMR = 0.93 (0.40-1.82) [8]; Internal comparisons:; [underlined: Highest exposure level attained]; Level 1 OR = 1.00 (Ref. value) [17]; Level 2 OR = 1.10 (0.51-2.38) [19]; Level 3 OR = 1.26 (0.39-4.08) [9]; [underlined: Duration of high exposures]; Level 1 OR = 1.00 (Ref. value) [17]; Level 2 OR = 1.77 (0.45-7.03) [5]; Level 3 OR = 0.96 (0.24-3.82) [4]
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975–1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from myeloid leukemia (ICD-8: 205).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975–1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60–74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; PMR = 1.57 (1.01-2.34) [24]; Additional:; [underlined: Acute myeloid leukemia (ICD-8: 205.0)]; PMR = 1.52 (0.85-2.52) [# not given]; [underlined: Chronic myeloid leukemia (ICD-8: 205.1)]; PMR = 1.84 (0.79-3.62) [# not given]
Reference: Walrath and Fraumeni (1984); Population: 1,007 deceased white male embalmers from the California Bureau of Funeral Directing and Embalming who died during 1925–1980. Death certificates obtained for all.; Outcome definition: Myeloid leukemia (ICD-8: 205) listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; Medium ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1916–1978. Birth year ranged from 1847 through 1959. Median age of death was 62 years. Most deaths were among embalmers with active licenses. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 8 myeloid leukemia deaths (including 2 acute monocytic leukemia); Expected: 4.3 myeloid leukemia deaths (including 0.3 acute monocytic leukemia); PMR = 1.86 (0.86–3.53)† [8]; Additional:; Observed: 6 acute myeloid leukemia deaths (including 2 acute monocytic leukemia); Expected: With 4.3 myeloid leukemia deaths expected, EPA used data from Selvin et al. (1983) on the expected ratio of AML:CML (2.2:1) among males ages 25+ to estimate 2.96 expected cases of AML out of the 4.3 expected myeloid leukemia deaths.; [underlined: Acute myeloid leukemia (ICD-8: 205.0)]; PMR = 2.03 (0.82–4.22)† [6]; †Note: EPA derived CIs using the Mid-P; Method; (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1983); Population: 1,132 deceased white male embalmers licensed to practice during 1902–1980 in New York who died during 1925–1980 identified from registration files. Death certificates obtained for 75% of potential study subjects (n = 1,678).; Outcome definition: Myeloid leukemia (ICD-8: 205) listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1902–1980. Median year of birth was 1901. Median year of initial license was 1931. Median age at death was 1968. Expected median duration of exposure was 37 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 7 myeloid leukemia deaths (including 1 acute monocytic leukemia); Expected: 4.4 myeloid leukemia deaths (including 0.3 acute monocytic leukemia); PMR = 1.59 (0.70–3.15)† [7]; Additional:; Observed: 6 acute myeloid leukemia deaths (including 1 acute monocytic leukemia); Expected: With 4.4 myeloid leukemia deaths expected, EPA used data from Selvin et al. (1983) on the expected ratio of AML:CML (2.2:1) among males ages 25+ to estimate 3.03 expected cases of AML out of the 4.4 expected myeloid leukemia deaths.; [underlined: Acute myeloid leukemia (ICD-8: 205.0)]; PMR = 1.98 (0.80–4.12)† [6]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Talibov et al. (2014); Population: Individuals from Finland, Iceland, Norway, and Sweden who were recorded in various censuses from 1960 to 1990. Acute myeloid leukemia cases identified by national registries up until 2003–2005 depending on the country.; Outcome definition: Diagnosis of incident cancer reported to the National Cancer Registries.; Design: Multicountry case-control study.; Analysis: HRs calculated for categories of cumulative formaldehyde exposure using conditional logistic regression controlling for year of birth, sex, country, solvents and other coexposures. A 10-year latency period was assumed.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. | Exposure assessment: Occupational history from census records were linked to the Nordic Occupational Cancer Study (NOCCA) JEM to code each cohort member as exposed to formaldehyde. Exposures were quantified based on the proportion of people in each occupation considered to be exposed and the mean level of exposure during specific periods. Coexposures to solvents was evaluated.; Duration and timing: Exposure period based on occupational histories prior to 1983. Duration and timing since first exposure were considered in the exposure metric but were not evaluated separated.; Variation in exposure:; Cumulative exposure:; Level 1 (unexposed); Level 2 (low): ≤0.171 ppm-years; Level 3 (moderate): 0.171–1.6 ppm-years; Level 4 (high): >1.6 ppm-years; Coexposures: Solvents and coexposures controlled for in multivariate models included: aliphatic and alicyclic hydrocarbons, aromatic hydrocarbons, [underlined: benzene], toluene, trichloroethylene, 111-trichloroethane, methylene chloride, [underlined: perchloroethylene], other organic solvents, and [underlined: ionizing radiation]. | Internal comparisons:; [underlined: Acute Myeloid Leukemia (ICD-9: 205.0)]; Level 1 OR = 1.00 (ref value) [13781]; Level 2 OR = 0.89 (0.81-0.97) [580]; Level 3 OR = 0.92 (0.83-1.03) [485]; Level 4 OR = 1.17 (0.91-1.51) [136]; p-trend = 0.07
Reference: Pira et al. (2014); Population: 2,750 workers employed at a laminated plastic factory in Italy for at least 180 days between 1947 and 2011 followed until May 2011. Deaths were identified from population registries. Vital status was 96.9% complete and only 3.1% lost to follow-up.; Outcome definition: Death certificates used to determine UCOD from myeloid leukemia (ICD-9: 205).; Design: Prospective cohort mortality study with external comparison group.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, and 5-year calendar periods using mortality rates from the Piedmont region.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (few cases). | Exposure assessment: Formaldehyde is a byproduct from the resins used in production process and all workers were presumed to have been exposed.; Duration and timing: Exposure period from 1947 through 2011. Median length of follow-up: 23.6 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated. | External comparisons:; Observed: 3 myeloid leukemia deaths Expected: 2.16 myeloid leukemia deaths based on authors’ assumption that 40% of leukemia deaths are from myeloid leukemia and 5.3 leukemia deaths were expected.; [underlined: Myeloid Leukemia (ICD-9: 205)]; SMR = 1.39 (0.35-3.78)† [3]; †Note: EPA derived CIs using the Mid-P Method [See Rothman and Boice (1979)]
Reference: Saberi Hosnijeh et al. (2013); Population: 241,465 men and women recruited from 10 European countries during 1992–2000. Participants were predominantly ages 35–70 at recruitment and were followed up through 2010.; Outcome definition: Incident primary leukemias.; Design: Prospective multinational cohort incidence study with internal comparison groups.; Analysis: HRs calculated controlling for age, sex, smoking, alcohol, physical activity, education, BMI, family history of cancer, country, other occupational exposures, and radiation.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. | Exposure assessment: Individual occupational histories obtained by questionnaire about ever working in any of 52 occupations considered to be at high risk of developing cancer. Occupational exposures estimated as “high,” “low,” and no exposure by linking to a JEM.; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure:; Exposure to formaldehyde:; Level 1 (none); Level 2 (low); Level 3 (high); Coexposures: Coexposure included pesticides, herbicides, insecticides, aromatic solvents, [underlined: benzene], chlorinated solvents, [underlined: trichloroethylene], metals, and contact with animals or animal products, [underlined: ionizing radiation].; [[underlined: As noted in] Appendix B.3.9:; Coexposures were not controlled for.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by low correlation between exposures in the general population.] | Internal comparisons:; Exposure to formaldehyde:; Level 1 RR = 1.00 (Ref. value) [130]; Level 2 RR = 1.02 (0.73-1.42) [49]; Level 3 RR = No data [0]
Reference: Blair et al. (2001); Population: White men, 30 years of age or older, identified from the Iowa cancer registry and the Minnesota hospital surveillance network during 1980–1983. Participation of eligible cases was 86% and approximately 77–79% for controls including 77% for surrogate respondents for deceased subjects.; Outcome definition: Diagnosis of leukemia was confirmed by pathology review for all cases.; Design: Population-based case-control study of 513 white men with leukemia from Iowa and Minnesota cancer surveillance networks. 1,087 controls were frequency matched on 5-year age groups, vital status, and state.; Analysis: ORs calculated for job titles, employment duration, and exposure intensity using unconditional logistic regression controlling for age, state, direct/surrogate response, and coexposures, including smoking. Analyses by year of first exposure were also conducted to evaluate latency.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Confounding possible. | Exposure assessment: Individual-level exposure estimates developed based on a JEM for each job held for more than 1 year, the industry where employed, and starting and ending year the job was held.; Exposure intensity and probability assessed for formaldehyde and other exposures. Exposure intensity refers to the level likely experienced and considered a TWA8 over a year.; Duration and timing: Exposure period based on occupational histories prior to 1983. Duration and timing since first exposure were evaluated.; Variation in exposure:; Intensity of exposure:; Level 1 (unexposed); Level 2 (low); Level 3 (high); Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Other exposures evaluated included benzene, other organic solvents, petroleum-based oils and greases, cooking oils, ionizing radiation, paper dusts, gasoline and exhaust vapors, paints, metals, wood dust, asbestos, asphalt, cattle, meat, solder fumes. However, analyses of formaldehyde exposures did not control for other exposures.] | Internal comparisons:; [underlined: Acute myeloid leukemia (ICD-9: 205.0)]; Level 1 OR = 1.0 (Ref. value) [118]; Level 2 OR = 0.9 (0.5-1.6) [14]; Level 3 no cases; [underlined: Chronic myeloid leukemia (ICD-9: 205.1)]; Level 1 OR = 1.0 (Ref. value) [38]; Level 2 OR = 1.3 (0.6-3.1) [7]; Level 3 OR = 2.9 (0.3-24.5) [1]; No notable findings were reported for duration of time since first exposure to formaldehyde.
Reference: Ott et al. (1989); Population: 29,139 men employed at two large chemical manufacturing facilities and a research and development center who worked during 1940–1978. Vital status was known for 96.4%. Death certificates were available for 5,785 known descendants (95.4%).; Outcome definition: Death certificates used to determine UCOD from nonlymphatic leukemia based on the ICD code in used at the time of death.; Design: Nested case-control study within a prospective cohort mortality study. Twenty-nine cases of nonlymphatic leukemia were frequency matched to 100 controls on time from hire to death.; Analysis: ORs calculated using unconditional logistic regression.; Related studies:; Rinsky et al. (1988); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association. Confounding possible. Low sensitivity due to rarity of exposure. | Exposure assessment: Individual-level exposure ascertained from employee’s work assignments linked to records on departmental usage of formaldehyde.; Duration and timing: Occupational exposures during 1940–1978. Timing of formaldehyde exposure not evaluated.; Variation in exposure: Ever/never; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9[underlined: :]; 21 different chemicals were evaluated including benzene with much cross exposure.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by rarity of coexposures among cases.] | Internal comparisons:; OR = 2.6 (0.44-8.59)† [2]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Stroup et al. (1986); Population: 2,239 white male members of the American Association of Anatomists from 1888 to 1969 who died during 1925−1979. Death certificates obtained for 91% with 9% lost to follow-up.; Outcome definition: Myeloid leukemia (ICD-8: 205) listed as cause of death on death certificates.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for selection bias. Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Confounding possible for ML. Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1925–1979. Median birth year was 1912. By 1979, 33% of anatomists had died. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [As noted in Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.; Anatomists may also be coexposed to stains, benzene, toluene, xylene, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | Leukemias:; 10 total reported; 1 lymphatic; 5 myeloid (3 chronic, 1 acute, 1 unspecified); 1 acute monocytic; 3 leukemia not otherwise specified; External comparisons:; [underlined: Chronic myeloid leukemia (ICD-8: 205.1)]; SMR = 8.8 (1.8–25.5) [3]

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: RR = relative risk; SMR = standardized mortality ratio; UCOD = underlying cause of death; OR = odds ratio; SRR = summary relative risk; SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis; TSFE = time since first exposure; URT = upper respiratory tract; LHP = lymphohematopoietic; HR = hazard ratio; PMR = proportionate mortality ratio; BMI = body mass index; JEM = job-exposure matrix.

##### Lymphatic leukemia

###### Epidemiological evidence

The most specific level of lymphatic leukemia diagnosis that is commonly reported across the epidemiological literature has been based on the first three digits of the Eighth or Ninth Revision of the ICD code (i.e., Lymphatic leukemia ICD-8: 204 and Lymphoid leukemia ICD-9: 204). Evidence describing the association between formaldehyde exposure and the specific risk of lymphatic leukemia was available from nine epidemiological studies—two case-control studies (Hauptmann et al., 2009; Blair et al., 2001) and seven cohort studies (Walrath and Fraumeni, 1983, 1984; Saberi Hosnijeh et al., 2013; Ott et al., 1989; Meyers et al., 2013; Hayes et al., 1990; Beane Freeman et al., 2009). Six of the cohort studies ascertained lymphatic leukemia diagnoses from death certificates and one examined incident cases (Saberi Hosnijeh et al., 2013). All studies reported lymphatic leukemia outcomes based on the ICD-8 or ICD-9 diagnostic code 204 without separate results for acute lymphocytic leukemia and CLL. One case-control study (Hauptmann et al., 2009) ascertained lymphatic leukemia diagnoses from death certificates whereas the other ascertained incident cases of lymphatic leukemia from a cancer registry and a hospital network (Blair et al., 2001). Both studies reported specific results for CLL; however, while diagnoses of lymphatic leukemia reviewed here are those identified according to the ICD codes used at the time of diagnoses, in the ICD-10 coding rubric, CLL would be included as NHL. Study details are provided in the evidence table for lymphatic leukemia (see Table 3-64). Study results for ICD-7 code 204 were not included because this code includes all leukemias. Details of the reported results of high, medium, and low confidence are provided in the evidence table for lymphatic leukemia (see Table 3-64) following the causal evaluation.

###### Consistency of the observed association

The point estimates and CIs of all eight informative studies were consistently around the null, which does not provide evidence of an association between formaldehyde exposure and the risk of developing or dying from lymphatic leukemia. The range of central relative effect estimates (selecting the highest exposure level results when there was more than one result) was from zero ((Walrath and Fraumeni, 1984); [zero cases]) to 2.6 ((Ott et al., 1989); [one case]) and both of these results were classified with low confidence. The three results classified with high or medium confidence were SMR = 0.71 in Meyers et al. (2013), OR = 1.0 in Hauptmann et al. (2009), and SMR = 1.15 in Beane Freeman et al. (2009). The study results presented in Table 3-64 (by confidence level and publication date) detail all of the reported associations between exposures to formaldehyde and the risks of developing or dying from lymphatic leukemia along with a summary graphic of any major limitation and the confidence classification of the effect estimate. Results are plotted in Figure 3-39.

###### Strength of the observed association

Summary effect estimates for the association between formaldehyde exposure and the risk of mortality from lymphatic leukemia ranged from zero to 2.6 and clustered around the null.

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants occurred before their lymphatic leukemia was detected and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and was done in a blinded fashion with respect to outcome status. None of the eight studies provided analyses of a temporal relationship between the timing of exposure and the diagnoses of lymphatic leukemia or deaths from lymphatic leukemia.

###### Exposure-response relationship

None of the studies evaluated the effect of duration of formaldehyde exposure on the mortality risk of lymphatic leukemia. There were only two sets of results, one classified with medium confidence and one with low confidence, which evaluated any form of exposure-response for increasing measures of formaldehyde exposure (Blair et al., 2001; Beane Freeman et al., 2009) and neither showed a pattern of increasing risk with increasing formaldehyde exposure.

###### Potential impact of selection bias, information bias, confounding bias, and chance

There was potential for selection bias in two studies that were only able to ascertain death certificated for 75–79% of the decedents (Walrath and Fraumeni, 1983; Ott et al., 1989), but there was no evidence that inclusion rates may have been related to either exposure or outcome, and thus, there is little concern about selection bias. Among the studies reporting on the risk of lymphatic leukemia, which only indicated the equivalent of ever/never exposure to formaldehyde, there was little potential for information bias. In fact, results consistently showed no evidence of an association—regardless of the quality of exposure assessment further. Confounding is another potential bias that could arise if another cause of lymphatic leukemia was statistically associated with formaldehyde exposure. However, there does not appear to be any evidence of negative confounding, which could have obscured a real but unobserved effect. While there did not appear to be an association between exposure to formaldehyde and the risk of lymphatic leukemia, given the limited database of specific results, and the possibility of biases that could obscure any true effect, the available epidemiological data are inadequate to conclude that formaldehyde is not likely to be carcinogenic to humans.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Generally consistent pattern of results around the null across high, medium, and low confidence studies, although there was a limited database from which to evaluate the potential risk to sensitive populations or lifestages.
- Strength and Precision: Studies reporting results for lymphatic leukemia were generally small with case counts ranging from zero to 36 cases with seven of nine studies reporting 10 or fewer cases. Variable strength of the association across studies reporting relative effect estimates from 0.71 to 2.6 all with confidence intervals including the null.
- Coherence: In each of the studies, the formaldehyde exposures among the study participants occurred before their lymphatic leukemia was detected.
- Dose-Response: In this database, there was an absence of exposure-response relationships showing that increased exposure to formaldehyde was associated with increased risk of lymphatic leukemia.

###### Causal evaluation

The human evidence synthesis judgments do not support a causal conclusion although there was a limited database. Although consistent observations of genotoxicity in peripheral blood lymphocytes across several occupational studies involving diverse exposure settings, these data were not interpreted as sufficient to further strengthen the judgment on the human evidence of lymphatic leukemia.

###### Conclusion

- The available epidemiological studies provide indeterminate evidence to assess the carcinogenic potential evidence of an association between formaldehyde exposure and an increased risk of lymphatic leukemia.

Figure 3-39 Epidemiological studies reporting lymphatic leukemia risk estimates

Results specifically for chronic lymphatic leukemia (CLL) are noted by these abbreviations. Details of the reported results of high, medium, and low confidence are provided in the evidence table for lymphatic leukemia (see Table 3-64). SMR = standardized mortality ratio; PMR = proportionate mortality ratio; RR = relative risk; OR = odds ratio. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 4]). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure.

Table 3-64 Epidemiological studies of formaldehyde exposure and risk of lymphatic leukemia

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Meyers et al. (2013); Population: 11,043 workers in three U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion.; Outcome definition: Death certificates used to determine both the UCOD from lymphocytic leukemia (ICD code in use at time of death).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates. Poisson regression analysis based on internal referents.; Related studies:; Stayner et al. (1985); Stayner et al. (1988); Pinkerton et al. (2004); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984. Geometric TWA8 exposures ranged from 0.09 to 0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 through 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:; SMR = 0.71 (0.26–1.56) [6]
Reference: Beane Freeman et al. (2009) with supplemental online tables.; Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the U.S. followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine UCOD from lymphatic leukemia (ICD-8: 204).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists, and monitoring data through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01–4.3). Median cumulative exposure = 0.6 ppm-years (range 0–107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 through 1980. Median length of follow-up: 42 years. Duration and timing since first exposure were not evaluated.; Variation in exposure:; Peak exposure:; Level 1 (>0 to <2.0 ppm); Level 2 (2.0 to <4.0 ppm); Level 3 (≥4.0 ppm); Average intensity:; Level 1 (>0 to <0.5 ppm); Level 2 (0.5 to <1.0 ppm); Level 3 (≥1.0 ppm); Cumulative exposure:; Level 1 (>0 to <1.5 ppm-years); Level 2 (1.5 to <5.5 ppm-years); Level 3 (≥5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders. | Internal comparisons:; [underlined: Peak exposure]; Unexposed RR = 0.27 (0.03–2.13) [1]; Level 1 RR = 1.00 (Ref. value) [14]; Level 2 RR = 0.81 (0.33–1.96) [8]; Level 3 RR = 1.15 (0.54–2.47) [14]; p-trend (exposed) >0.50;; p-trend (all) = 0.30; [underlined: Average intensity]; Unexposed RR = 0.26 (0.03–2.01) [1]; Level 1 RR = 1.00 (Ref. value) [22]; Level 2 RR = 0.92 (0.39–2.16) [7]; Level 3 RR = 0.88 (0.37–2.11) [7]; p-trend (exposed) >0.50;; p-trend (all) >0.50; [underlined: Cumulative exposure]; Unexposed RR = 0.24 (0.03–1.88) [1]; Level 1 RR = 1.00 (Ref. value) [21]; Level 2 RR = 0.57 (0.21–1.54) [5]; Level 3 RR = 1.02 (0.47–2.21) [10]; p-trend (exposed) = 0.46;; p-trend (all) = 0.41; External comparisons:; SMR_Unexposed_ = 0.26 (0.04–1.82) [1]; SMR_Exposed_ = 1.15 (0.83–1.59) [36]
Reference: Hauptmann et al. (2009); Population: 6,808 embalmers and funeral directors who died during 1960–1986. Identified from registries of the National Funeral Directors’ Association, licensing boards, and state funeral directors’ associations, NY State Bureau of Funeral Directors, and CA Funeral Directors and Embalmers. Deaths were identified from the National Death Index. Next of kin interviews conducted for 96% of cases and 94% of controls.; Outcome definition: Death certificates used to determine UCOD from CLL (ICD-8: 204.1).; [Note that while CLL was classified as lymphocytic leukemia in ICD-8, in ICD-10, it is included as non-Hodgkin lymphoma]; Design: Nested case-control study within a prospective cohort study.; Analysis: ORs calculated using unconditional logistic regression adjusted for date of birth, age at death, sex, data source, and smoking. Lagged exposures were evaluated to account for cancer latency.; Related studies:; Hayes et al. (1990); Walrath and Fraumeni (1983); Walrath and Fraumeni (1984); Note: The original cohorts from these three related studies were combined in Hauptmann et al. (2009) and follow-up was extended so the case-series overlap and are not independent. However, the three related cohorts used external reference groups for comparison while Hauptmann et al. (2009) select internal controls, which were independent of the reference groups used in the other studies.; [underlined: Confidence in effect estimate:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Occupational history obtained by interviews with next of kin and coworkers using detailed questionnaires. Exposure was assessed by linking questionnaire responses to an exposure assessment experiment providing measured exposure data. Exposure levels (peak, intensity, and cumulative) were assigned to each individual using a predictive model based on the exposure data. The model explained 74% of the observed variability in exposure measurements.; Multiple exposure metrics including duration (mean = 33.1 years in cases), # of embalming, peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1932 through 1986. Duration of exposure was evaluated. Duration is also a surrogate for time because first exposure since dates of death were closely related to cessation of workplace exposures; Variation in exposure:; For variations in exposure from table 3 in the publication:; Level 1 (no exposure to embalming); For variations in exposure from table 4 in the publication:; Level 1 (<500 embalming); Duration of exposure: Level 2 (<20 years); Level 3 (20–34 years); Level 4 (>34 years); Number of embalming:; Level 2 (500−1,422); Level 3 (1,423–3,068); Level 4 (>3,068); Cumulative exposure:; Level 2 (≤4,058 ppm-hrs); Level 3 (4,059–9,253 ppm-hrs); Level 4 (≥9,253 ppm-hrs); Average intensity (while embalming):; Level 2 (≤1.4 ppm); Level 3 (>1.4–1.9 ppm); Level 4 (>1.9 ppm); TWA8 formaldehyde intensity:; Level 2 (≤0.10 ppm); Level 3 (>0.10–0.18 ppm); Level 4 (>0.18 ppm); Peak Exposure:; Level 2 (<7.0 ppm); Level 3 (7.0 to <9.3 ppm); Level 4 (>9.3 ppm); Coexposures: None evaluated.; [As noted in Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | Internal comparisons:; Embalming:; Never: OR = 1.0 (Ref. value); [# not given]; Ever: OR = 1.0 (0.5–1.9); [# not given]
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975–1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from lymphatic leukemia (ICD-8: 204).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation, which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975–1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60–74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; PMR = 0.74 (0.29–1.53) [7]
Reference: Saberi Hosnijeh et al. (2013); Population: 241,465 men and women recruited from 10 European countries during 1992–2000. Participants were predominantly aged 35–70 at recruitment and were followed up through 2010.; Outcome definition: Incident primary leukemias.; Design: Prospective multinational cohort incidence study with internal comparison groups.; Analysis: HRs calculated controlling for age, sex, smoking, alcohol, physical activity, education, BMI, family history of cancer, country, other occupational exposures, and radiation.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. | Exposure assessment: Individual occupational histories obtained by questionnaire about ever working in any of 52 occupations considered to be at high risk of developing cancer. Occupational exposures estimated as “high,” “low,” and no exposure by linking to a JEM.; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure:; Exposure to formaldehyde:; Level 1 (none); Level 2 (low); Level 3 (high); Coexposures: Coexposure included pesticides, herbicides, insecticides, aromatic solvents, [underlined: benzene], chlorinated solvents, [underlined: trichloroethylene], metals, contact with animals or animal products, [underlined: ionizing radiation].; [[underlined: As noted in] Appendix B.3.9: Coexposures were not controlled for.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by low correlation between exposures in the general population.] | Internal comparisons:; Exposure to formaldehyde:; Level 1 RR = 1.00 (Ref. value) [130]; Level 2 RR = 1.08 (0.81–1.45) [64]; Level 3 RR = 1.38 (0.44–4.35) [3]
Reference: Blair et al. (2001); Population: White men, 30 years of age or older, identified from the Iowa cancer registry and the Minnesota hospital surveillance network during 1980–1983. Participation of eligible cases was 86% and approximately 77–79% for controls including 77% for surrogate respondents for deceased subjects.; Outcome definition: Diagnosis of leukemia was confirmed by pathology review for all cases.; Design: Population-based case-control study of 513 white men with leukemia from Iowa and Minnesota cancer surveillance networks. 1,087 controls were frequency matched on 5-year age groups, vital status, and state.; Analysis: ORs calculated for job titles, employment duration and exposure intensity using unconditional logistic regression controlling for age, state, direct/surrogate response and coexposures, including smoking. Analyses by year of first exposure conducted.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Confounding possible. | Exposure assessment: Individual-level exposure estimates developed based on a JEM for each job held for more than 1 year, the industry where employed, and starting and ending year the job was held.; Exposure intensity and probability assessed for formaldehyde and other exposures. Exposure intensity refers to the level likely experienced and considered a TWA8 over a year.; Duration and timing: Exposure period based on occupational histories prior to 1983. Duration and timing since first exposure were evaluated.; Variation in exposure:; Intensity of exposure:; Level 1 (unexposed); Level 2 (low); Level 3 (high); Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Other exposures evaluated included [underlined: benzene], other organic solvents, petroleum-based oils and greases, cooking oils, ionizing radiation, paper dusts, gasoline and exhaust vapors, [underlined: paints, metals, wood dust, asbestos], asphalt, cattle, meat, solder fumes. However, analyses of formaldehyde exposures did not control for other exposures.] | Internal comparisons:; [underlined: Acute lymphatic leukemia (ICD-9:204.0)]; No exposed cases; [underlined: Chronic lymphatic leukemia (ICD-9: 204.1)]; Level 1 OR = 1.0 (Ref. value) [483]; Level 2 OR = 1.2 (0.7–1.8) [29]; Level 3 OR = 0.6 (0.1–5.3) [1]; No notable findings were reported for duration of time since first exposure to formaldehyde.
Reference: Ott et al. (1989); Population: 29,139 men employed at two large chemical manufacturing facilities and a research and development center who worked during 1940–1978. Vital status was known for 96.4%. Death certificates were available for 5,785 known descendants (95.4%).; Outcome definition: Death certificates used to determine UCOD from lymphatic leukemia based on the ICD code in used at the time of death.; Design: Nested case-control study within a prospective cohort mortality study. Eighteen cases of lymphatic leukemia were frequency matched to 100 controls on time from hire to death.; Analysis: ORs calculated using unconditional logistic regression.; Related studies:; Rinsky et al. (1988); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association. Confounding possible. Low sensitivity due to rarity of exposure. | Exposure assessment: Individual-level exposure ascertained from employee’s work assignments linked to records on departmental usage of formaldehyde.; Duration and timing: Occupational exposures during 1940–1978. Timing of formaldehyde exposure not evaluated.; Variation in exposure: Ever/never; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: 21 different chemicals were evaluated including [underlined: benzene] with much cross exposure.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by rarity of coexposures among cases.] | Internal comparisons:; OR = 2.6 (0.13–13.0)† [1]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1984); Population: 1,007 deceased white male embalmers from California who died during 1925–1980. Death certificates obtained for all.; Outcome definition: Lymphatic leukemia (ICD-8: 204) listed as cause of death on death certificate.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1916–1978. Birth year ranged from 1847 through 1959. Median age of death was 62 years. Most deaths were among embalmers with active licenses. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 0 lymphatic leukemia deaths; Expected: 2.2 lymphatic leukemia deaths; PMR = 0 (0–1.36)† [0 vs. 2.2 expected]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Walrath and Fraumeni (1983); Population: 1,132 deceased white male embalmers licensed to practice during 1902–1980 in New York who died during 1925–1980 identified from registration files. Death certificates obtained for 75% of potential study subjects (n = 1,678).; Outcome definition: Lymphatic leukemia (ICD-8: 204) listed as cause of death on death certificate.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing:; Occupational exposure preceding death during 1902–1980. Median year of birth was 1901. Median year of initial license was 1931. Median age at death was 1968. Expected median duration of exposure was 37 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 4 lymphatic leukemia deaths; Expected: 2.6 lymphatic leukemia deaths; PMR = 1.54 (0.49–3.71)† [4]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis; UCOD = underlying cause of death; GSD = geometric standard deviation; SMR = standardized mortality ratio; RR = relative risk; TWA8 = 8-hour time-weighted average; LHP = lymphohematopoietic; PMR = proportionate mortality ratio; BMI = body mass index; JEM = job-exposure matrix; OR = odds ratio.

##### Multiple myeloma

###### Epidemiological evidence

The most specific classification of multiple myeloma diagnosis that is commonly reported across the epidemiological literature has been based on the first three digits of the Eighth or Ninth Revision of the ICD code without further differentiation (i.e., Multiple myeloma ICD-8/9: 203). Evidence describing the association between formaldehyde exposure and the risk of developing or dying from multiple myeloma was available from 14 epidemiological studies—five case-control studies (Pottern et al., 1992; Ott et al., 1989; Heineman et al., 1992; Hauptmann et al., 2009; Boffetta et al., 1989) and nine cohort studies (Stellman et al., 1998; Pira et al., 2014; Meyers et al., 2013; Hayes et al., 1990; Edling et al., 1987b; Dell and Teta, 1995; Coggon et al., 2014; Beane Freeman et al., 2009; Band et al., 1997). One set of reported results from Fryzek et al. (2005) was classified as not informative due to likely confounding; for details see Appendix B.3.9. Details of the reported results of high, medium, and low confidence are provided in the evidence table for multiple myeloma (see Table 3-65) following the causal evaluation.

###### Consistency of the observed association

The results of these studies appear to be mixed with some showing non-significant increases in risk and other showing non-significant decreases in risk. Nine of the 14 studies were low confidence (Stellman et al., 1998; Pottern et al., 1992; Pira et al., 2014; Ott et al., 1989; Edling et al., 1987b; Dell and Teta, 1995; Boffetta et al., 1989) with many results based on fewer than five cases. However, only the study by Beane Freeman et al. (2009) reported a result with high confidence showing an association between peak formaldehyde exposure and risk of multiple myeloma. The study results presented in Table 3-65 (by confidence level and publication date) and plotted in Figure 3-40 detail all of the reported associations between exposures to formaldehyde and the risks of developing or dying from multiple myeloma.

The first four studies shown at the left in Figure 3-40 followed the health of groups of occupationally exposed workers in three different industries and did not have individual-level exposure estimates (Hayes et al., 1990; Edling et al., 1987b; Dell and Teta, 1995). Respectively, these were: (1) workers making grinding wheels bound with formaldehyde resins, (2) embalmers, and (3) workers manufacturing plastics—professions known to be exposed to formaldehyde. Importantly, all of these professions were exposed to high peak concentrations of formaldehyde. Edling et al. (1987b) reported that the workers making grinding wheels bound with formaldehyde resins were exposed to peak formaldehyde levels of up to 20–30 mg/m^3^ (15–23 ppm). Embalmers (Hayes et al., 1990) were also exposed to high peak formaldehyde concentrations with mean exposures of more than 2 ppm and peaks as high as 8.7 ppm (Stewart et al., 1992). Workers at the plastics manufacturing facilities studied by Dell and Teta (1995) were exposed to formaldehyde, formaldehyde resins, and formaldehyde molding compounds. An independent occupational hygiene survey of facilities producing similar products reported peak exposure for these activities of 1.88 ppm, 30.45 ppm, and 60.77 ppm, respectively (Stewart et al., 1987). The results of these three studies are displayed beneath the header of “Population-level exposure assessment.” All three studies showed elevated RRs of multiple myeloma mortality as measured by the mortality ratios; although, none of the three was statistically robust enough to decrease the likelihood of chance as an alternative explanation. The Hayes et al. (1990) result (PMR = 1.37; 95% CI 0.84–2.12; n = 20) was classified with medium confidence but the other two results from Edling et al. (1987b) (SMR = 4.0; 95% CI 0.45–14.44; n = 2) and Dell and Teta (1995) (SMR = 2.62; 95% CI 0.85–6.11; n = 8) were classified with low confidence.

The second set of studies (n = 10) is displayed in Figure 3-40 (Stellman et al., 1998; Pottern et al., 1992; Ott et al., 1989; Meyers et al., 2013; Heineman et al., 1992; Hauptmann et al., 2009; Coggon et al., 2014; Boffetta et al., 1989; Beane Freeman et al., 2009; Band et al., 1997) beneath the header of “Individual-level exposure assessment.” In principle, a general strength of this second set of studies was their use of individualized exposure data; however, the quality of the exposure assessment for each individual varied considerably across this set of studies. These 10 studies with individual-level exposure assessment can be divided into two groups based on the methods of individual exposure assessment. The first grouping gathered minimal information (e.g., questionnaire data on “ever” exposure to formaldehyde) on formaldehyde exposure (Stellman et al., 1998; Pottern et al., 1992; Heineman et al., 1992; Boffetta et al., 1989). The second grouping focused on workers who were occupationally exposed to formaldehyde and used work assignments or job histories matched to exposure data to assess workers’ formaldehyde exposures (Ott et al., 1989; Meyers et al., 2013; Hauptmann et al., 2009; Coggon et al., 2014; Beane Freeman et al., 2009; Band et al., 1997).

The exposure assessment methodology for the first grouping of four studies with individual-level exposures was especially crude. Exposure assessment was limited to either a one-time questionnaire asking participants to check off a box if they were “ever” exposed to formaldehyde in the workplace or in daily life (Stellman et al., 1998; Boffetta et al., 1989) or using the occupation listed on individuals’ most recent annual tax records to estimate previous occupational formaldehyde exposure as “none,” “possible,” or “probable” (Pottern et al., 1992; Heineman et al., 1992). While the large size of these studies was considered to be a strength, the weaknesses of their relatively low-quality exposure assessment outweighed that strength. It is well known that the use of low-quality exposure data in epidemiological studies may preclude the ability to detect all but the strongest association.

The second grouping of studies, with relatively higher quality individual-level exposure to formaldehyde, examined occupational histories at different points in time and linked this to measured or estimated exposures (Ott et al., 1989; Meyers et al., 2013; Hauptmann et al., 2009; Coggon et al., 2014; Beane Freeman et al., 2009; Band et al., 1997). While the relative effect estimates for multiple myeloma mortality in each of these cohorts compared to the general population did not show elevated risks (relative effect estimates of: 0.8, 1.4, 1.0, 0.94, 1.24, 0.99), two studies (Coggon et al., 2014; Beane Freeman et al., 2009) showed somewhat higher risks when analyses focused on the workers with highest peak exposure. Beane Freeman et al. (2009) evaluated results by each worker’s highest formaldehyde concentration during a “peak” exposure event, by average intensity of exposure, by cumulative exposure, and by duration of exposure. Peak exposure events were defined as short-term exposures (<15 minutes) that exceeded the TWA formaldehyde intensity (Beane Freeman et al., 2009). Workers’ peak exposures were defined as the highest concentration among their peak exposure events. In Beane Freeman et al. (2009), the highest peak exposure category represents the workers who had ever experienced short-term peak exposure to ≥4.0 ppm. The Beane Freeman et al. (2009) results in the high category of peak exposures were RR = 2.04 (95% CI 1.01–4.12). In Coggon et al. (2014), the “high” category of exposure represented workers who ever had a job in the highest formaldehyde exposure category (≥2 ppm). The Coggon et al. (2014) results in the high exposure category were, however, relatively weak SMR = 1.18 versus 0.99 for all workers.

Hauptmann et al. (2009) and Ott et al. (1989) assessed individual-level exposure but only presented results specific to formaldehyde exposures for the study population as a whole. Similarly, the study of garment workers (Meyers et al., 2013) relied on individual measures of the timing of exposure but did not have formaldehyde concentration data beyond the industrial hygiene data used to plan the study (Stayner et al., 1988). Continuous area monitoring showed that formaldehyde levels were relatively constant with no substantial peak levels over the work shift (Stayner et al., 1988). The results from Meyers et al. (2013) are mixed, with the strongest evidence showing a statistically significant decreased risk among workers with the longest duration of formaldehyde exposure in analyses compared to internal referents with less than a 3-year exposure duration (SRR = 0.28; 95% CI 0.08–0.99).

In summary, among all the studies that used individual-level exposure assessment, the study with the highest quality exposure assessment methodology was the National Cancer Institute study (Beane Freeman et al., 2009) among industrial workers at facilities either using formaldehyde or producing formaldehyde. Beane Freeman et al. (2009) reported on three different, but related, measures of exposure to formaldehyde based on different exposure assessment techniques highlighting peak, cumulative and average exposures and showed elevated risk across all three measures; the most pronounced effects showed a two-fold increased risk of mortality from multiple myeloma associated with the highest level of peak exposure to formaldehyde (RR = 2.04; 95% CI 1.01–4.12).

The three studies with population-level exposure assessment, (Hayes et al., 1990; Edling et al., 1987b; Dell and Teta, 1995), all had very high peak exposure and were consistent with Beane Freeman et al. (2013) in showing an elevated risk although none was able to rule out chance. The large population studies with only crude measures of formaldehyde exposure reported mixed results with only a slightly higher risk for those judged to be “Probably” exposed (see Figure 3-40). The studies of industrial workers did not show increased risks in their populations as a whole but did report somewhat higher risks among the workers with highest exposure when individual-level exposures were considered (Coggon et al., 2014; Beane Freeman et al., 2009).

A better understanding of the etiologic progression of multiple myeloma may be needed to interpret these findings but there is some consistent epidemiological evidence suggesting an association between peak formaldehyde exposures and increased risk of multiple myeloma and possibly an increased risk at shorter durations, which could select out the responsive individuals leaving the nonresponsive individuals without additional risks. However, it could also be the case from these data that only peak exposures are associated with multiple myeloma.

###### Strength of the observed association

While reported relative effect estimates were consistently elevated above the null value of one across the studies, the magnitude of the relative effect estimates varied with the quality of the exposure assessment. Studies with higher quality exposure data based on individual-level exposure assessment generally reported higher relative effect estimates (stronger associations)

Setting aside the large population-based studies with crude exposure assessment (Stellman et al., 1998; Pottern et al., 1992; Heineman et al., 1992; Boffetta et al., 1989) and focusing on individual-level exposure results where possible, the strength of the associations ranged from 1.2 to 4.0, but the upper end of that range was based on two studies with very few formaldehyde-exposed cases. The results at the highest levels of peak formaldehyde exposure showed an approximately two-fold relative increase in risk of death from multiple myeloma (Beane Freeman et al., 2009).

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants started prior to their multiple myeloma diagnosis and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and was done in a blinded fashion with respect to outcome status. The epidemiological literature for formaldehyde and multiple myeloma describes only one study that evaluates the impact of TSFE (Meyers et al., 2013); however, while those results showed what appeared to be a slight downward trend toward lower risks at shorter times since first exposure, the CIs around those estimated risks were wide and overlapped substantially. Such findings do not add much additional information.

###### Exposure-response relationship

There was limited evidence of exposure-response relationships in three multiple myeloma studies. The study by Beane Freeman et al. (2009) reported on three different measures of exposure to formaldehyde and showed elevated risk across all three measures, most strongly for peak exposure (RR = 2.04; 95% CI 1.01–4.12) for the highest category (trend p = 0.08). There was also a finding of greater risks of multiple myeloma at shorter durations of exposure compared to longer durations; in two analyses of duration using both internal and external comparison groups, those workers with the longest duration of exposure (10+ years) were at lower risk than those with 3–9 years of exposure. This would be inconsistent with an exposure-response pattern for duration of exposure or cumulative exposure but is not necessarily inconsistent with the finding of an exposure-response for higher levels of peak exposure. Coggon et al. (2014) reported a very modest increase in risk among those workers in the high exposure category (SMR = 1.18; 95% CI 0.57–2.18); however, the risk among workers in the low/moderate category was even higher (SMR = 1.47; 95% CI 0.82–2.43). Pottern et al. (1992) reported increasing relative risks with the qualitative likelihood of exposure with “possible” exposure having RR = 1.1 (95% CI 0.8–1.6) and “probable” exposure having RR = 1.6 (95% CI 0.4–5.3).

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias is an unlikely bias in the epidemiological studies of multiple myeloma as the case-control studies evaluated exposure status without regard to outcome status and had participation levels of 77–100% and each of the cohort studies included at least 79% of eligible participants and lost fewer than 6% of participants over the course of mortality follow-up. The healthy worker effect and the healthy worker survivor effect could obscure a truly larger effect of formaldehyde exposure in analyses based on “external” comparisons with mortality in the general population (Ott et al., 1989; Meyers et al., 2013; Hayes et al., 1990; Edling et al., 1987b; Dell and Teta, 1995; Coggon et al., 2014; Beane Freeman et al., 2009), but would not influence analyses using “internal” or matched comparison groups (Stellman et al., 1998; Pottern et al., 1992; Heineman et al., 1992; Hauptmann et al., 2009; Boffetta et al., 1989; Beane Freeman et al., 2009).

Differential exposure misclassification is considered unlikely among these studies of multiple myeloma mortality. Random measurement error or nondifferential misclassification has the effect of causing bias toward the null, thereby obscuring potentially real effects by underestimating their magnitude. This may explain the generally null findings of the four large studies that relied on very crude assessments of exposure (Stellman et al., 1998; Pottern et al., 1992; Heineman et al., 1992; Boffetta et al., 1989).

Confounding is a potential bias that could arise if another cause of multiple myeloma was also associated with formaldehyde exposure. There does not appear to be any evidence of confounding that would provide an alternative explanation for the observed association of formaldehyde exposure with increased risk of multiple myeloma seen in these studies. Known risk factors for multiple myeloma include age, sex, race, and exposure to benzene (Vlaanderen et al., 2011). Chemical, and other coexposures that have not been independently associated with multiple myeloma are not expected to confound results. Pentachlorophenol is considered to be a likely carcinogen (U.S. EPA, 2010) and the only study with likely coexposure to pentachlorophenol was classified as not informative due to the likelihood of confounding (Robinson et al., 1987). Risks of multiple myeloma are higher with advancing age, among men, and the age-adjusted mortality rate in black Americans was more than twice as high as among white Americans in 2008 (NCI, 2012). All of the epidemiological studies controlled for age and sex. Only one study reported results according to race (Hayes et al., 1990) who reported statistically significant increased risks among “nonwhites” showing a PMR = 3.69 (95% CI 1.59–7.26).

Benzene was not noted as a coexposure in the studies of workers making grinding wheels (Edling et al., 1987b), garment plant workers (Meyers et al., 2013), or embalmers (Hayes et al., 1990) and consequently, would not be expected to be a confounder of those results. In the study of workers manufacturing plastics, Dell and Teta (1995) examined possible coexposures with benzene but concluded that there were no obvious common exposures. Benzene exposures were not reported in the study of British industrial workers (Coggon et al., 2003); although, it is a possible coexposure. However, in a cohort of U.S. industrial workers with similar occupational activities, benzene was specifically assessed as a potential confounder among the U.S. industrial workers (Beane Freeman et al., 2009) and found not to be a confounder.

A single high confidence result supports an association between peak formaldehyde exposures and increased risks of multiple myeloma (Beane Freeman et al., 2009) with support from three results of studies of high peak formaldehyde exposure settings with low to medium confidence (Hayes et al., 1990; Edling et al., 1987b; Dell and Teta, 1995). However, risk estimates using other exposure metrics from the same study with the high confidence result (Beane Freeman et al., 2009) did not find increased risks and it is not known which metric of exposure is likely to be the most biologically relevant. Bias is unlikely to explain these findings, but chance could be an alternative explanation.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Results were heterogeneous with many reporting results near the null—but effects were consistently elevated in four studies where workers were exposed to high peak exposures including one high confidence result.
- Strength and Precision: The strength of the association showing an approximate 1.2- to 4-fold increase in risk with the highest quality evidence showing a two-fold increase in risk with high peak exposures.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from myeloid leukemia, allowing time for cancer induction, latency, and mortality although only one study evaluated the impact of time since first exposure.
- Dose-Response: Limited evidence of an exposure-response trend from a single high confidence study showing that increased exposure to formaldehyde was associated with increased risk of multiple myeloma.

###### Causal evaluation

The causal evaluation for formaldehyde exposure and the risk of developing or dying from multiple myeloma placed the greatest weight on five particular considerations: (1) the observations of increases in risk across one high, one medium, and two low confidence studies of occupational formaldehyde levels, but limited to groups of people who experienced high peak exposures; analyses based on other exposure metrics did not report associations in several populations; (2) the strength of the association showing an approximate 1.2- to 4-fold increase in risk with the highest quality evidence showing a two-fold increase in risk with high peak exposures; (3) the limited evidence of an exposure-response trend from a single high confidence study showing that increased exposure to formaldehyde was associated with increased risk of multiple myeloma; (4) reasonable confidence that alternative explanations are ruled out, including bias and confounding within individual studies or across studies, but chance could be an alternative explanation; and (5) confidence was diminished by reports of inverse relationships with duration of exposure and TSFE.

Given the uncertainties outlined above, and although formaldehyde is genotoxic, the consistent observations of genotoxicity in peripheral blood lymphocytes observed across several occupational studies were not interpreted as sufficient to further strengthen the judgment on the human evidence of multiple myeloma beyond slight.

###### Conclusion

- The available epidemiological studies provide slight evidence of an association consistent with causation between formaldehyde exposure and an increased risk of multiple myeloma—primarily with respect to peak exposure.

Figure 3-40 Epidemiological studies reporting multiple myeloma risk estimates

Details of the reported results of high, medium, and low confidence are provided in the evidence table for multiple myeloma (see Table 3-65). SMR = standardized mortality ratio; PMR = proportionate mortality ratio; RR = relative risk; OR = odds ratio. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 3]). Results are grouped by the exposure-assessment methodology (e.g., population-level versus individual-level) and the source of the cancer data (e.g., American Cancer Society or Danish Cancer Registry) or type of occupation of exposed workers (e.g., industrial workers). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure. *Note that the CIs for Band et al. (1997) are 90% rather than 95%.

Table 3-65 Epidemiological studies of formaldehyde exposure and risk of multiple myeloma

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Beane Freeman et al. (2009) with supplemental online tables; Population: 25,619 workers employed at 10 formaldehyde-using or formaldehyde-producing plants in the U.S. followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. 676 workers (3%) were lost to follow-up. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine UCOD from multiple myeloma (ICD-8: 203).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias); [NB: Checkoway et al. (2015) below]; Reference: Beane Freeman et al. (2009) as re-analyzed by Checkoway et al. (2015) with differences noted; Population: No differences.; Outcome definition: Death certificates used to determine UCOD from acute and chronic myeloid leukemia (ICD-8: 205.0 and 205.1).; Design: No differences.; Analysis: HRs estimated using Cox proportional hazards models controlling for age, sex, and race; adjusted for pay category compared to workers in the redefined lowest exposed category. Did not control for calendar year as did Beane Freeman et al. (2009). Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); Checkoway et al. (2015) [reviewed here]; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D due to reclassification of peak exposures as unexposed) with attenuation of association. | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists, and monitoring data through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01–4.3). Median cumulative exposure = 0.6 ppm-years (range 0–107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 to 1980. Median length of follow-up: 42 years. Duration and timing since first exposure were not evaluated.; Variation in exposure:; Peak exposure:; Level 1 (>0 to <2.0 ppm); Level 2 (2.0 to <4.0 ppm); Level 3 (≥4.0 ppm); Average intensity: Level 1 (>0 to <0.5 ppm); Level 2 (0.5 to <1.0 ppm); Level 3 (≥1.0 ppm); Cumulative exposure:; Level 1 (>0 to <1.5 ppm-years); Level 2 (1.5 to <5.5 ppm-years); Level 3 (≥5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders and found not be confounders.; [[underlined: As noted in] Appendix B.3.9: There was no information on smoking; however, according to Blair et al. (1986), “The lack of a consistent elevation for tobacco-related causes of death, however, suggests that the smoking habits among this cohort did not differ substantially from those of the general population.” | Internal comparisons:; [underlined: Peak exposure]; Unexposed RR = 2.74 (1.18–6.37) [11]; Level 1 RR = 1.00 (Ref. value) [14]; Level 2 RR = 1.65 (0.76–3.61) [13]; Level 3 RR = 2.04 (1.01-4.12) [21]; p-trend (exposed) = 0.08;; p-trend (all) >0.50; [underlined: Average intensity]; Unexposed RR = 2.18 (1.01–4.70) [11]; Level 1 RR = 1.00 (Ref. value) [25]; Level 2 RR = 1.40 (0.68–2.86) [11]; Level 3 RR = 1.49 (0.73–3.04) [12]; p-trend (exposed) >0.50;; p-trend (all) >0.50; [underlined: Cumulative exposure]; Unexposed RR = 1.79 (0.83–3.89) [11]; Level 1 RR = 1.00 (Ref. value) [28]; Level 2 RR = 0.46 (0.18–1.20) [5]; Level 3 RR = 1.28 (0.67–2.44) [15]; p-trend (exposed) >0.50;; p-trend (all) >0.50; External comparisons:; SMR_Unexposed_ = 1.78 (0.99–3.22) [11]; SMR_Exposed_ = 0.94 (0.71–1.25) [48]; Checkoway; External comparisons:; SMR_Unexposed_ = 1.82 (1.01–3.29) [11]; SMR_Exposed_ = 0.93 (0.70–1.24) [48]
Reference: Coggon et al. (2014); Population: 14,008 British men employed in six chemical industry factories that produced formaldehyde. Cohort mortality followed from 1941 through 2012. Cause of deaths was known for 99% of 5,185 deaths through 2000. Similar cause of death information not provided on 7,378 deaths through 2012. Vital status was 98.9% complete and only 1.1% lost to follow-up through 2003. Similar information not provided on deaths through 2012.; Outcome definition: Death certificates used to determine cause of deaths from multiple myeloma (ICD-9: 203).; Design: Cohort mortality study with external comparison group.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941–1982. Duration was evaluated as more, or less, than 1 year only among the high exposure group. Timing since first exposure was not evaluated.; Variation in exposure:; Highest exposure level attained; Level 1 (Background); Level 2 (low/moderate); Level 3 (High); Duration of high exposures; Level 1 (<1 year); Level 2 (1 year or more); Coexposures: Not evaluated as potential confounders. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers.; [underlined: Asbesto]s is associated with URT cancers, but not with LHP cancers.; Other coexposures are not known risk factors for this outcome.; Authors stated that the extent of coexposures was expected to be low.; Potential for confounding may be mitigated by low coexposures.] | External comparisons:; SMR = 0.99 (0.66–1.43) [28]; Within-study external comparisons:; Highest exposure level attained; Level 1 SMR = 0.31 (0.06–0.91) [3]; Level 2 SMR = 1.47 (0.82–2.43) [15]; Level 3 SMR = 1.18 (0.57–2.18) [10]
Reference: Meyers et al. (2013); Population: 11,043 workers in three U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through; 2008 with 99.7% completion; Outcome definition: Death certificates used to determine both the UCOD from multiple myeloma (ICD code in use at time of death).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Stayner et al. (1985); Stayner et al. (1988); Pinkerton et al. (2004); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984. Geometric TWA8 exposures ranged from 0.09 to 0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 through 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were evaluated.; Variation in exposure:; Duration of exposure:; Level 1 (<3 years); Level 2 (3–9 years); Level 3 (10+ years); Time since first exposure:; Level 1 (<10 years); Level 2 (10–19 years); Level 3 (20+ years); Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:; SMR = 1.24 (0.79–1.86) [23]; Within-study external comparisons:; [underlined: Duration of exposure:]; Level 1 SMR = 1.16 (0.50–2.29) [8]; Level 2 SMR = 2.03 (1.01–3.64) [11]; Level 3 SMR = 0.64 (0.17–1.64) [4]; [underlined: Time since first exposure (TSFE):]; Level 1 SMR = 1.73 (0.04–9.61) [1]; Level 2 SMR = 1.63 (0.34–4.76) [3]; Level 3 SMR = 1.18 (0.71–1.84) [19]; [underlined: Year of first exposure:]; <1963 SMR = 1.28 (0.71–2.11) [15]; 1963–70 SMR = 0.81 (0.22–2.08) [4]; 1971+ SMR = 2.16 (0.59–5.52) [4]; Internal comparisons:; [underlined: Duration of exposure:]; Level 1 SRR = 1.00 (Ref. value) [8]; Level 2 SRR = 1.22 (0.46–3.26) [11]; Level 3 SRR = 0.28 (0.08–0.99) [4]
Reference: Hauptmann et al. (2009); Population: 6,808 embalmers and funeral directors who died during 1960–1986. Identified from registries of the National Funeral Directors’ Association, licensing boards and state funeral directors’ associations, NY State Bureau of Funeral Directors, and CA Funeral Directors and Embalmers. Deaths were identified from the National Death Index. Next of kin interviews conducted for 96% of cases and 94% of controls.; Outcome definition: Death certificates used to determine UCOD from multiple myeloma (ICD-8: 203).; Design: Nested case-control study within a prospective cohort mortality study using two internal comparison groups; the first composed of those who had never embalmed (one case and 55 controls) and the second composed of those who had fewer than 500 embalmings (5 cases and 83 controls).; Analysis: ORs calculated using unconditional logistic regression adjusted for date of birth, age at death, sex, data source, and smoking. Lagged exposures were evaluated to account for cancer latency.; Results from the second internal comparison group with <500 embalmings were selected to increase statistical stability.; Related studies:; Hayes et al. (1990); Walrath and Fraumeni (1983); Walrath and Fraumeni (1984); Note: The original cohorts from these three related studies were combined in Hauptmann et al. (2009) and follow-up was extended so the case-series overlap and are not independent.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Occupational history obtained by interviews with next of kin and coworkers using detailed questionnaires.; Exposure was assessed by linking questionnaire responses to an exposure assessment experiment providing measured exposure data. Exposure levels (peak, intensity, and cumulative) were assigned to each individual using a predictive model based on the exposure data. The model explained 74% of the observed variability in exposure measurements.; Multiple exposure metrics including duration (mean = 33.1 years in cases), # of embalming, peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1932 through 1986. Year of birth ranged from 1876 through 1959. Year of deaths ranged from 1960 through 1986. Duration of exposure was evaluated. Duration is also a surrogate for time since first exposure since dates of death were closely related to cessation of workplace exposures; Variation in exposure: Ever/never; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation.]; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Ever embalming: OR = 1.4 (0.4–5.6); [# not given]
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975–1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from multiple myeloma (ICD-8: 205).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation, which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975–1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60–74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; PMR = 1.37 (0.84–2.12) [20]; Additional:; [underlined: By Race]; White PMR = 0.97 (0.50–1.69) [12]; Nonwhite PMR = 3.69 (1.59–7.26) [8]
Reference: Pira et al. (2014); Population: 2,750 workers employed at a laminated plastic factory in Italy for at least 180 days between 1947 and 2011 followed until May 2011. Deaths were identified from population registries. Vital status was 96.9% complete and only 3.1% lost to follow-up.; Outcome definition: Death certificates used to determine UCOD from multiple myeloma (ICD-9: 203).; Design: Prospective cohort mortality study with external comparison group.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, and 5-year calendar periods using mortality rates from the Piedmont region.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (few cases). | Exposure assessment: Formaldehyde is a byproduct from the resins used in production process and all workers were presumed to have been exposed.; Duration and timing: Exposure period from 1947 through 2011. Median length of follow-up: 23.6 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated | External comparisons:; Observed: 0 multiple myeloma deaths; Expected: 2 multiple myeloma deaths; [underlined: Myeloid Leukemia (ICD-9: 205)]; SMR = 0 (0–1.50)† [0]; †Note: EPA derived CIs using the Mid-P Method [See Rothman and Boice (1979)]
Reference: Stellman et al. (1998); Population: 317,424 U.S. men enrolled in the American Cancer Society’s Cancer Prevention Study II during 1982 with sufficient data on occupation. Cohort mortality followed until August 1988 with 98% complete follow-up.; Outcome definition: Death certificates used to determine cause of deaths from multiple myeloma (ICD-9: 203).; Design: Prospective cohort study with internal comparison group.; Analysis: RR calculated using Poisson regression controlling for sex, age, smoking.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Individual-level exposure ascertained from questionnaire on occupation with specific exposure to formaldehyde based on checkbox. Formaldehyde analyses limited to workers not in wood-related occupations.; Duration and timing: Occupational exposures prior to 1982. Timing of formaldehyde exposure not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Wood dust excluded.; [[underlined: As noted in] Appendix B.3.9:; Coexposures included: [underlined: asbestos] and [underlined: wood dust].; However, these coexposures are not associated with LHP endpoints so confounding is unlikely.] | Internal comparisons:; RR = 0.74 (0.27–2.02) [4]
Reference: Band et al. (1997); Population: 30,157 male workers with at least 1 year of employment accrued by January 1950. Followed through December 1982. Loss to follow-up was less than 6.5% for workers exposed to the sulfate process (67% of original cohort of 30,157) and less than 20% for workers exposed to the sulfite process.; Outcome definition: Cause of death obtained from the National Mortality Database based on ICD version in effect at time of death and standardize to ICD-9 version; multiple myeloma (ICD-9 203).; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the Canadian population.; [underlined: Confidence in effect estimates:] ^a^; ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible. | Exposure assessment: Occupational data limited to hire and termination dates for all workers and type of chemical process of pulping (sulfate vs. sulfite). No job-specific data available. Presumed exposure to formaldehyde known to be used in the plant.; Formaldehyde is known to be an exposure for pulp and paper mill workers: job-specific median exposures ranging from 0.04 to 0.4 ppm with peaks as high as 50 ppm (Korhonen et al., 2004).; Duration and timing: Duration and timinge since first exposure were not evaluated.; Variation in exposure:; No variation in formaldehyde exposure was reported. Results presented by pulping process (sulfate vs. sulfite) but there is no information on differential exposures between the two processes.; Coexposures: Not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9: Potential confounders for these outcomes include chlorophenols, [underlined: acid mists, dioxin, and perchloroethylene] and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:; [underlined: All workers]; SMR = 0.80 (90% CI 0.48–1.29) [12]
Reference: Dell and Teta (1995); Population: 5,932 men employed at a New Jersey plastics manufacturing plant for at least 7 months during 1946–1967. Cohort mortality followed through 1988.; Vital status was 94% complete and only 6% lost to follow-up. Death certificates obtained for 98%.; Outcome definition: Death certificates used to determine UCOD from multiple myeloma based on ICD code at time of death.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected numbers; of deaths from the U.S. and local populations.; [underlined: Confidence in effect estimates:] ^a^; SUMMARY for MM: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible. | Exposure assessment: Presumed exposure to formaldehyde known to be used in the plant. Only 111 men had assignments involving formaldehyde.; Duration and timing: Exposures during 1946–1967. Duration and timing since first exposure were not evaluated.; Variation in exposure:; By department: Plant Services and Research and Development.; By pay status: salaried and hourly.; Coexposures: Not evaluated as confounders.; [As noted in Appendix B.3.9 coexposures include: acrylonitrile, [underlined: asbestos, benzene], carbon black, epichlorohydrin, PVC (vinyl chloride), [underlined: styrene], and toluene and would likely be positively correlated with formaldehyde exposure.; Asbestos is not associated with LHP cancers.; Benzene and styrene were not evaluated as potential confounders and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:; [underlined: All salaried workers]; SMR = 2.62 (0.85–6.11) [5]; [underlined: Research and Development: Hourly workers]; SMR = 2.73 (0.55–7.97) [3]
Reference: Pottern et al. (1992); Population: Danish women registered in both the National Cancer Registry and pension fund. All women with a specific occupational history other than “homemaker” were included.; Outcome definition: Incident cases of multiple myeloma reported to the Danish Cancer Registry during 1970–1984.; Design: Population-based case-control study of 363 women with 1,517 age- and sex-matched controls alive at time of case diagnosis.; Analysis: ORs calculated for occupation, industry, and likelihood of exposure using logistic regression controlling for age.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimated by industrial hygienists based on occupation listed on most recent annual income tax documents and the industry associated with that occupation.; Duration and timing: Exposure period preceding cancer incidence (<1984). Duration and timing since first exposure were not evaluated.; Variation in exposure:; Likelihood of exposure:; Level 1 (unexposed); Level 2 (possible); Level 3 (probable); Coexposures: Many other compounds were identified and evaluated as independent risk factors.; [As noted in Appendix B.3.9: Other exposures evaluated included 19 categories grouping 47 substances.; Coexposures were not evaluated for confounding but exposure to organic solvents (including benzene) and radiation were not risk factors for multiple myeloma so confounding is unlikely.] | Internal comparisons:; Likelihood of exposure; Level 1 RR = 1.0 (Ref. value) [303]; Level 2 RR = 1.1 (0.8–1.6) [56]; Level 3 RR = 1.6 (0.4–5.3) [4]
Reference: Heineman et al. (1992); Population: Danish men registered in both the National Cancer Registry and pension fund. All men with a specific occupational history were included.; Outcome definition: Incident cases of multiple myeloma reported to the Danish Cancer Registry during 1970–1984. 92% of cases were histologically confirmed.; Design: Population-based case-control study of 1,098 men with 4,169 age- and sex-matched controls alive at time of case diagnosis.; Analysis: ORs calculated for occupation, industry, and likelihood of exposure using logistic regression controlling for age.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimated by industrial hygienists based on occupation listed on most recent tax documents.; Duration and timing: Exposure period preceding cancer incidence (<1984). Duration and timing since first exposure were not evaluated.; Variation in exposure:; Likelihood of exposure:; Level 1 (unexposed); Level 2 (possible); Level 3 (probable); Coexposures: Other compounds were identified and evaluated as independent risk factors including: gasoline, oil products, engine exhausts, benzene, dyes, phthalates, vinyl chloride, asbestos, and pesticides.; [As noted in Appendix B.3.9: Other exposures evaluated included 19 categories grouping 47 substances.; Asbestos is not a risk factor for LHP.; “Possible” benzene exposure was associated with MM but not “probable” benzene exposure, so confounding is considered to be unlikely.] | Internal comparisons:; Likelihood of exposure; Level 1 RR = 1.0 (Ref. value) [913]; Level 2 RR = 1.0 (0.8–1.3) [144]; Level 3 RR = 1.1 (0.7–1.6) [41]
Reference: Boffetta et al. (1989); Population: 508,637 U.S. men and 676,613 women enrolled in the American Cancer Society’s Cancer Prevention Study II during 1982 with sufficient data on occupation. Cohort mortality followed until August 1986 with 98.5% complete follow-up.; Outcome definition: Death certificates used to determine cause of deaths from incident cases of multiple myeloma (ICD-9: 203) since follow-up began.; Design: Population-based matched nested case-control within prospective cohort study.; Analysis: RR calculated using Poisson regression controlling for sex, age, smoking, education, diabetes, X-ray treatment, farming, pesticide, and herbicide exposure.; [underlined: Confidence in effect estimates:] ^a^; SUMMARY: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Low sensitivity (few exposed cases). | Exposure assessment: Individual-level exposure ascertained from questionnaire on occupation with specific exposure to formaldehyde based on checkbox.; Duration and timing: Occupational exposures prior to 1982. Timing of formaldehyde exposure not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Various coexposures were controlled for in the analyses.; [[underlined: As noted in] Appendix B.3.9: Matching controlled for sex, age, ethnic group, residence, smoking, education, diabetes, X-ray treatment, farming, pesticide, and herbicide exposure.; Other coexposures were not associated with LHP cancers.] | Internal comparisons:; OR = 1.8 (0.6–5.7) [4]
Reference: Ott et al. (1989); Population: 29,139 men employed at two large chemical manufacturing facilities and a research and development center who worked during 1940–1978. Vital status was known for 96.4%. Death certificates were available for 5,785 known descendants (95.4%).; Outcome definition: Death certificates used to determine UCOD from multiple myeloma based on the ICD code in used at the time of death.; Design: Nested case-control study within a prospective cohort mortality study. Twenty cases of multiple myeloma were frequency matched to 100 controls on time from hire to death.; Analysis: ORs calculated using unconditional logistic regression.; Related studies:; Rinsky et al. (1988); [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association. Confounding possible. Low sensitivity due to rarity of exposure. | Exposure assessment: Individual-level exposure ascertained from employee’s work assignments linked to records on departmental usage of formaldehyde.; Duration and timing: Occupational exposures during 1940–1978. Timing of formaldehyde exposure not evaluated.; Variation in exposure: Ever/never; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: 21 different chemicals were evaluated including [underlined: benzene] with much cross exposure.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by rarity of coexposures among cases.] | Internal comparisons:; OR = 1.0 (0.05–4.9) [1]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Edling et al. (1987b); Population: 521 Swedish male blue collar workers in an abrasive production plant with at least 5 years of employment between 1955 and 1983. Cohort mortality followed through 1983 with 97% known vital status.; Outcome definition: Cancer mortality ascertained using UCOD from the National Death Registry. Cancer incidence ascertained from the National Cancer Registry. Mortality and incidence of multiple myeloma based on ICD-8:203.; Design: Cohort mortality and incidence study with external comparison group.; Analysis: SMRs calculated using sex, age, and calendar-year-specific Swedish mortality rates.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Manufacture of grinding wheels bound by formaldehyde resins exposed workers to 0.1−1 mg/m^3^ formaldehyde; 59 workers manufacturing abrasive belts had low exposure to abrasives with intermittent exposures with peaks up to 20–30 mg/m^3^ formaldehyde.; Duration and timing: Exposures during 1955–1983. Duration and timing since first exposure were evaluated.; Variation in exposure: Not evaluated.; Coexposures: Aluminum oxide and silicon carbide were coexposures but were not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures are not known risk factors for this outcome.] | External comparisons:; [underlined: Cancer mortality]; No increase reported; [underlined: Cancer Incidence]; SMR = 4.0 (0.67–13.2)† [2]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis; UCOD = underlying cause of death; GSD = geometric standard deviation; SMR = standardized mortality ratio; RR = relative risk; TWA8 = 8-hour time-weighted average; URT = upper respiratory tract; LHP = lymphohematopoietic; PMR = proportionate mortality ratio; BMI = body mass index; JEM = job-exposure matrix; OR = odds ratio.

##### Hodgkin lymphoma

###### Epidemiological evidence

The most specific level of Hodgkin lymphoma diagnosis that is commonly reported across the epidemiological literature has been based on the first three digits of the Eighth or Ninth Revision of the ICD code (i.e., Hodgkin disease ICD-8/9: 201). Evidence describing the association between formaldehyde exposure and the specific risk of Hodgkin lymphoma was available from 15 epidemiological studies—one case-control study (Gérin et al., 1989) and 14 cohort studies (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Solet et al., 1989; Robinson et al., 1987; Meyers et al., 2013; Matanoski, 1989; Hayes et al., 1990; Hansen and Olsen, 1995; Hall et al., 1991; Coggon et al., 2003; Beane Freeman et al., 2009; Band et al., 1997; Andjelkovich et al., 1995). Details of the reported results of high, medium, and low confidence are provided in the evidence table for Hodgkin lymphoma (see Table 3-66) following the causal evaluation.

Note that the confidence judgments are for the confidence in the reported effect estimate of an association from each study and not a confidence judgment in the overall study. Four sets of reported results from Fryzek et al. (2005), Hall et al. (1991), Solet et al. (1989), and Matanoski (1989) were classified as not informative due to multiple biases and uncertainties; for details see Appendix B.3.9.

###### Consistency of the observed association

The results of the 12 informative studies were not consistent. The study of the largest cohort of formaldehyde-exposed workers (Beane Freeman et al., 2009) reported an elevated risk of dying from Hodgkin lymphoma for the cohort as a whole (SMR = 1.42; 95% CI 0.96–2.1; 27 cases) and a pronounced increase in risk among those workers with the highest peak formaldehyde exposures (RR = 3.96; 95% CI; 1.31–12.02; 11 cases)—results that were classified with medium confidence. However, the other medium confidence result from Gérin et al. (1989) was an OR = 0.5 (95% CI 0.2–1.2; 8 cases). The results of the other 10 studies (all low confidence) were largely based on small numbers of cases and yielded generally unstable CIs surrounding the RR (see Figure 3-41).

Compared with other LHP cancers, the 5-year survival rate for Hodgkin lymphoma is relatively high at 86% and mortality is rare. In contrast, the survival rate for myeloid leukemia is 38%. The high survival rate for Hodgkin lymphoma may indicate that mortality data are not as good a proxy for incidence data for this LHP cancer subtype. In this instance, these mortality data are potentially inadequate to evaluate causation. The low mortality rate for Hodgkin lymphoma results in few exposed cases and very low statistical power, which may have contributed to the apparently discordant results. Aside from the Beane Freeman et al. (2009) result (medium confidence), which reported 25 exposed deaths from Hodgkin lymphoma, only one other cohort study observed more than 10 deaths from Hodgkin lymphoma among exposed subjects (Hansen and Olsen, 1995); this study reported 12 observed deaths against 12 expected deaths—a result classified with low confidence.

The study results presented in Table 3-66 (by confidence level and publication date) detail all of the reported associations between exposures to formaldehyde and the risks of developing or dying from Hodgkin lymphoma along with a summary graphic of any major limitation and the confidence classification of the effect estimate. Results are plotted in Figure 3-41.

###### Strength of the observed association

Summary effect estimates for the association between formaldehyde exposure and Hodgkin lymphoma were highly variable and the risk of developing or dying from Hodgkin lymphoma were predominantly less than one (unity) and ranged from zero to 4.0 (Edling et al., 1987b). While the summary effect estimate from the study by Beane Freeman et al. (2009) was RR = 1.42 (95% CI 0.96–2.10), the strength of the association was substantially higher among those workers exposed to the highest peak levels (RR = 3.96). Beane Freeman et al. (2009) further showed plots presenting the RR from the internal analyses for each endpoint and for each year of follow-up. The association of Hodgkin lymphoma with formaldehyde exposure is not only seen for the complete 2004 follow-up when the average length of follow-up was 42 years, but throughout the cohort experience (see Figure 1 in (Beane Freeman et al., 2009)). These plots show that during the 1970s and 1980s, the RR ≈ 8 and remained elevated at about RR = 4 through the end of follow-up in 2004. Such a consistent finding of a strong effect over many years of follow-up reduces the possibility that the results for the full follow-up period could be due to chance.

###### Temporal relationship of the observed association

In each of the studies, the formaldehyde exposures among the study participants occurred before their Hodgkin lymphoma was detected and in the studies that ascertained individual-level exposures, the estimation of formaldehyde exposures was based on job titles and was done in a blinded fashion with respect to outcome status. Only one study (Band et al., 1997) reported on analyses of the temporal relationship showing that risks were highest in workers with 15 or more years since first formaldehyde exposure and 15 or more years of exposure duration (SMR = 1.62; 95% CI 0.55–3.71). However, this finding is without corroboration for Hodgkin lymphoma.

###### Exposure-response relationship

Only two studies evaluated any other form of exposure-response for increasing measures of formaldehyde exposure (Coggon et al., 2003; Beane Freeman et al., 2009). Coggon et al. (2003) reported a lower risk of dying from Hodgkin lymphoma among “highly” exposed workers based on a single death. Beane Freeman et al. (2009) reported a clear exposure-response relationship between increasing levels of peak formaldehyde and increased risk of dying from Hodgkin lymphoma among exposed workers (p = 0.01). Compared to exposed workers in the lowest exposure category of peak exposure, those in the middle category were at more than two-fold higher risk (RR = 3.30; 95% CI 1.04–10.50) while those workers in the highest category were at four-fold higher risk (RR = 3.96; 95% CI 1.31–12.02). Beane Freeman et al. (2009) also reported exposure-response relationships between increased risk of dying from Hodgkin lymphoma among exposed workers based on average formaldehyde intensity (OR range: 1.61–2.48; p = 0.05) and cumulative exposure (OR range: 1.30–1.71; p = 0.08).

###### Potential impact of selection bias, information bias, confounding bias, and chance

Selection bias is an unlikely bias in the epidemiological studies of Hodgkin lymphoma as the one case-control study was population-based and used other cancer cases as controls with exposure status evaluated without regard to outcome status and had a participation level of 83%. Each of the cohort studies included at least 72% of eligible participants and lost fewer than 9% of participants over the course of mortality follow-up.

The healthy worker effect including the healthy worker survivor effect could obscure a truly larger effect of formaldehyde exposure in analyses based on “external” comparisons with mortality in the general population (Walrath and Fraumeni, 1983, 1984; Stroup et al., 1986; Robinson et al., 1987; Meyers et al., 2013; Hayes et al., 1990; Hansen and Olsen, 1995; Coggon et al., 2003; Beane Freeman et al., 2009; Band et al., 1997; Andjelkovich et al., 1995), but would not influence analyses using “internal” or matched comparison groups (Gérin et al., 1989; Beane Freeman et al., 2009).

Information bias is unlikely to have resulted in bias away from the null—especially as the exposure assessment in these studies were generally of high quality; however, random measurement error or nondifferential misclassification is almost certain to have resulted in some bias toward the null among these studies of Hodgkin lymphoma.

Chemical exposures that have not been independently associated with Hodgkin lymphoma are not expected to confound results. The main support for concluding there is a slight association of formaldehyde exposure with increased risk of Hodgkin lymphoma is from the results for peak exposures reported by Beane Freeman et al. (2009) who specifically examined the potential for confounding from 11 substances including benzene and found that controlling for these exposures did not meaningfully change the results. This provides evidence against potential confounding by these coexposures. There does not appear to be any evidence of confounding that would provide an alternative explanation for the observed association of formaldehyde exposure with increased risk of Hodgkin lymphoma reported by Beane Freeman et al. (2009). The evidence of an association with peak exposures reported by Beane Freeman et al. (2009) suggests an association whose risk increases with greater exposure.

###### Summary of Human Evidence Synthesis Judgments, Causal Evaluation, and Conclusion

###### Summary of human evidence synthesis judgments

The following factors were most influential to the causal evaluation and synthesis conclusion:

- Consistency and Study Confidence: Results were heterogeneous. Statistically robust evidence of increased risk of Hodgkin lymphoma in the highest peak exposure group among industrial workers. However, the results from the other medium confidence result showed some evidence of decreased risk and the other 10 studies (all low confidence) were largely based on small numbers of cases and yielded generally unstable CIs surrounding the effect estimate.
- Strength and Precision: Effect estimates ranged from zero to 4.0 with one result showing a statistically significant increase in risk.
- Coherence: Biologically coherent temporal relationship consistent with a pattern of exposure to formaldehyde and subsequent death from myeloid leukemia, allowing time for cancer induction, latency, and mortality although only one study evaluated the impact of time since first exposure.
- Dose-Response: Limited evidence of an exposure-response trend from a single medium confidence study showing that increased peak exposure to formaldehyde was significantly associated with increased risk of Hodgkin lymphoma.

###### Causal evaluation

The human evidence synthesis judgments are suggestive of an association between high peak exposure and the risk of Hodgkin lymphoma. Given the uncertainties outlined above, and although formaldehyde is genotoxic, the consistent observations of genotoxicity in peripheral blood lymphocytes observed across several occupational studies were not interpreted as sufficient to further strengthen the judgment on the human evidence of Hodgkin lymphoma beyond slight.

###### Conclusion

- The available epidemiological studies provide slight evidence of an association consistent with causation between formaldehyde exposure and an increased risk of Hodgkin lymphoma.

Figure 3-41 Epidemiological studies reporting multiple Hodgkin lymphoma estimates

Details of the reported results of high, medium, and low confidence are provided in the evidence table for Hodgkin lymphoma (see Table 3-66). SMR = standardized mortality ratio; PMR = proportionate mortality ratio; RR = relative risk; OR = odds ratio. For each measure of association, the number of exposed cases is provided in brackets (e.g., [n = 7]). For studies reporting results on multiple metrics of exposure, each metric is included; however, only the highest category of each exposure metric is presented in the figure. *Note that the CIs for Band et al. (1997) are 90% rather than 95%.

Table 3-66 Epidemiological studies of formaldehyde exposure and risk of Hodgkin lymphoma

Study | Exposures | Results: effect estimate (95% CI) [# of cases]
Reference: Beane Freeman et al. (2009) with supplemental online tables; Population: 25,619 workers employed at 10 formaldehyde-using or formaldehydeproducing plants in the U.S. followed from either the plant start-up or first employment through 2004. Deaths were identified from the National Death Index with remainder assumed to be living. Vital status was 97.4% complete and only 2.6% lost to follow-up.; Outcome definition: Death certificates used to determine underlying cause of death from Hodgkin disease (ICD-8: 201).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: RRs estimated using Poisson regression stratified by calendar year, age, sex, and race; adjusted for pay category compared to workers in lowest exposed category. Lagged exposures were evaluated to account for cancer latency.; SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Blair et al. (1986); Hauptmann et al. (2003); [underlined: Confidence in effect estimates:] ^a^; HIGH (No appreciable bias) | Exposure assessment: Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists, and monitoring data from 1966 through 1980.; Median TWA (over 8 hours) = 0.3 ppm (range 0.01–4.3).; Median cumulative exposure = 0.6 ppm-years (range 0–107.4).; Multiple exposure metrics including peak, average, and cumulative exposures were evaluated using categorical and continuous data.; Duration and timing: Exposure period from <1946 through 1980. Median length of follow-up: 42 years. Duration and timing since first exposure were evaluated.; Variation in exposure:; For all variations in exposure:; Level 1 (unexposed); Peak exposure:; Level 2 (>0 to <2.0 ppm); Level 3 (2.0 to <4.0 ppm); Level 4 (≥4.0 ppm); Average intensity:; Level 2 (>0 to <0.5 ppm); Level 3 (0.5 to <1.0 ppm); Level 4 (≥1.0 ppm); Cumulative exposure:; Level 2 (>0 to <1.5 ppm-years); Level 3 (1.5 to <5.5 ppm-years); Level 4 (≥5.5 ppm-years); Coexposures: Exposures to 11 other compounds were identified and evaluated as potential confounders and found not be confounders.; [[underlined: As noted in] Appendix B.3.9: There was no information on smoking, however, according to Blair et al. (1986), “The lack of a consistent elevation for tobacco-related causes of death, however, suggests that the smoking habits among this cohort did not differ substantially from those of the general population.”] | Internal comparisons:; [underlined: Peak exposure]; 1994 Follow-up:; Highest peak RR = 3.30 (0.98–11.10) (p-trend = 0.04); 2004 Follow-up:; [underlined: Peak exposure]; Level 1 RR = 0.67 (0.12–3.6) [2]; Level 2 RR = 1.00 (Ref. value) [6]; Level 3 RR = 3.30 (1.04–10.50) [8]; Level 4 RR = 3.96 (1.31–12.02) [11]; p-trend (exposed) = 0.01;; p-trend (all) = 0.004; [underlined: Average intensity]; Level 1 RR = 0.53 (0.11–2.66) [2]; Level 2 RR = 1.00 (Ref. value) [10]; Level 3 RR = 2.48 (0.84–7.32) [9]; Level 4 RR = 1.61 (0.73–3.39) [6]; p-trend (exposed) = 0.05;; p-trend (all) = 0.03; [underlined: Cumulative exposure]; Level 1 RR = 0.42 (0.09–2.05) [2]; Level 2 RR = 1.00 (Ref. value) [14]; Level 3 RR = 1.71 (0.66–4.38) [7]; Level 4 RR = 1.30 (0.40–4.19) [4]; p-trend (exposed) = 0.08;; p-trend (all) = 0.06; [underlined: Duration of exposure]; No evidence of association (data not shown).; [underlined: Time since first exposure]; >0–15 years RR = 1.00 (Ref. value); >15–25 years RR = 1.54 (0.42–5.62); >25–35 years RR < 1.54; >35 years RR < 1.54; External comparisons:; SMR_Unexposed_ = 0.70 (0.17–2.80) [2]; SMR_Exposed_ = 1.42 (0.96–2.10) [25]
Reference: Gérin et al. (1989); Population: Male residents of Montreal, Canada aged 35–70 years. 4,510 eligible incident cancer cases were identified during 1979–1985 from 19 major area hospitals, which report to the Quebec Tumor Registry over 97% of all cancer diagnoses from the Montreal area. Interviews and questionnaires completed for 3,726 subjects (83% of eligible cases). 18% of interviews were completed by next of kin.; Outcome definition: Histologically confirmed diagnosis of Hodgkin lymphoma (ICD: 201); Design: Population-based case-control study of 53 formaldehyde-exposed men with Hodgkin lymphoma. Cases were compared with two groups; first, against other cancer cases excluding those diagnosed with lung cancer (n = 2,599), and second against 533 male population controls selected from electoral list in the Montreal area.; Analysis: ORs calculated by levels of a composite exposure index using logistic regression controlling for age, ethnic group, socio-economic status, smoking, and dirtiness of jobs held (white vs. blue collar).; Related studies:; Siemiatycki et al. (1987); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimates developed based on a complete and detailed occupational history ascertained by interviewers using a standardized questionnaire. A team of chemists and hygienists translated each job into a list of potential formaldehyde exposures based on their confidence level, the frequency of exposure, and the duration of exposure.; Duration and timing: Exposure period based on occupational histories prior to cancer diagnosis. Duration of exposure was evaluated.; Variation in exposure: For cancer sites with fewer than 30 cases exposed to formaldehyde, results for the exposure subgroups were not shown.; Coexposures: Additional occupational and nonoccupational potential confounders were included in analyses when the estimated exposure-disease OR changed by more than 10%. | Internal comparisons:; [underlined: Compared to other cancers]; OR = 0.5 (0.2–1.2) [8]; [underlined: Compared to population controls]; OR = 0.5 (0.2–1.4) [8]
Reference: Meyers et al. (2013); Population: 11,043 workers in three U.S. garment plants exposed for at least 3 months. Women comprised 82% of the cohort. Vital status was followed through 2008 with 99.7% completion; Outcome definition: Death certificates used to determine the underlying cause of death from Hodgkin lymphoma (ICD code in use at time of death).; Design: Prospective cohort mortality study with external and internal comparison groups.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; Related studies:; Stayner et al. (1985); Stayner et al. (1988); Pinkerton et al. (2004); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984. Geometric TWA8 exposures ranged from 0.09 to 0.20 ppm. Overall geometric mean concentration of formaldehyde was; 0.15 ppm (GSD 1.90 ppm). Area measures showed constant levels without peaks. Historically earlier exposures may have been substantially higher.; Duration and timing: Exposure period from 1955 through 1983. Median duration of exposure was 3.3 years. More than 40% exposures <1963. Median time since first exposure was 39.4 years. Duration and timing since first exposure were evaluated.; Variation in exposure: Not evaluated.; Coexposures: Study population specifically selected because industrial hygiene surveys at the plants did not identify any chemical exposures other than formaldehyde that were likely to influence findings. | External comparisons:; SMR = 0.95 (0.26–2.44) [4]
Reference: Coggon et al. (2003); Population: 14,014 British men employed in six chemical industry factories that produced formaldehyde. Cohort mortality followed from 1941 through 2000. Vital status was 98.9% complete and only 1.1% lost to follow-up.; Outcome definition: Death certificates used to determine cause of deaths from Hodgkin disease (ICD-9: 201).; Design: Cohort mortality study with external comparison group.; Analysis: SMRs based on English and Welsh age- and calendar-year-specific mortality rates.; Related studies:; Acheson et al. (1984); Gardner et al. (1993); Coggon et al. (2003); [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓; (Potential bias toward the null↓); IB: Exposure Group B; latency was not evaluated; Cf: Potential confounding | Exposure assessment: Exposure assessment based on data abstracted from company records. Jobs categorized as background, low, moderate, high, or unknown levels.; Duration and timing: Occupational exposure during 1941–1982. Duration and timing since first exposure were not evaluated.; Variation in exposure:; TWA exposure; Level 1 (low); Level 2 (moderate); Level 3 (high); Coexposures: Not evaluated as potential confounders. Potential low-level exposure to [underlined: styrene], ethylene oxide, epichlorhydrin, solvents, [underlined: asbestos], chromium salts, and cadmium.; [[underlined: As noted in] Appendix B.3.9: [underlined: Styrene] is associated with LHP cancers.; Asbestos is associated with URT cancers, but not with LHP cancers.; Other coexposures are not known risk factors for this outcome.; Authors stated that the extent of coexposures was expected to be low. Potential for confounding may be mitigated by low coexposures.] | External comparisons:; SMR = 0.70 (0.26–1.53) [6]; Within-study external comparisons:; Worked in high exposure jobs; SMR = 0.36 (0.01–2.01) [1]
Reference: Walrath and Fraumeni (1983); Population: 1,132 deceased white male embalmers licensed to practice during 1902–1980 in New York who died during 1925–1980 identified from registration files. Death certificates obtained for 75% of potential study subjects (n = 1,678).; Outcome definition: Hodgkin disease (ICD8: 201) listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓; (Potential bias toward the null↓); IB: Exposure Group A; latency not evaluated | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing:; Occupational exposure preceding death during 1902–1980. Median year of birth was 1901. Median year of initial license was 1931. Median age at death was 1968.; Expected median duration of exposure was 37 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 2 Hodgkin disease deaths; Expected: 2.3 Hodgkin disease deaths; PMR = 0.87 (0.15–2.87)† [7]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))
Reference: Band et al. (1997); Population: 30,157 male workers with at least 1 year of employment accrued by January 1950. Followed through December 1982. Loss to follow-up was less than 6.5% for workers exposed to the sulfate process (67% of original cohort of 30,157) and less than 20% for workers exposed to the sulfite process.; Outcome definition: Cause of death obtained from the National Mortality Database based on ICD version in effect at time of death and standardize to ICD-9 version. Hodgkin lymphoma: ICD-9 201; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected numbers of deaths from the Canadian population.; [underlined: Confidence in effect estimates:] ^a^; ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible. | Exposure assessment: Occupational data limited to hire and termination dates for all workers and type of chemical process of pulping (sulfate vs. sulfite). No job-specific data available. Presumed exposure to formaldehyde known to be used in the plant. Formaldehyde is known to be an exposure for pulp and paper mill workers: job-specific median exposures ranging from 0.04 to 0.4 ppm with peaks as high as 50 ppm (Korhonen et al., 2004); Duration and timing: Duration and timing since first exposure were evaluated.; Variation in exposure:; No variation in formaldehyde exposure was reported. Results presented by pulping process (sulfate vs. sulfite) but there is no information on differential exposures between the two processes; Coexposures: Not evaluated as confounders.; [[underlined: As noted in] Appendix B.3.9: Potential confounders for these outcomes include chlorophenols, [underlined: acid mists, dioxin, and perchloroethylene] and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:; [underlined: All workers]; SMR = 0.71 (90% CI 0.33–1.34) [7]; Work duration <15 years; TSFE < 15 years; SMR = 0.53 (90% CI 0.14–1.37) [3]; Work duration ≥15 years; TSFE ≥ 15 years; SMR = 1.62 (90% CI 0.55–3.71) [4]
Reference: Andjelkovich et al. (1995); Population: 3,929 automotive industry iron foundry workers exposed from 1960 through 1987 and followed through 1989.; Outcome definition: UCOD obtained from Social Security Administration, Pension Benefit Informations, and National Death Index); Hodgkin lymphoma: ICD 201; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex-, age-, race-, and calendar-year-specific U.S. mortality rates.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Individual-level exposure status (yes/no, quartile) based on review of work histories by an industrial hygienist.; Exposure assessment blinded to outcome.; Independent testing of iron foundries by NIOSH reported a range from 0.02 ppm to 18.3 ppm (cited in IPCS (1989) Env. Health Criteria 89: Formaldehyde).; Duration and timing: Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: [underlined: Nickel] and chromium are associated with URT but not LHP.; Other coexposures are not known risk factors for these outcomes.] | External comparisons:; SMR_Unexposed_ = 0.70 (0.01–3.88) [1]; SMR_Exposed_ = 0.72 (0.01–4.00) [1]
Reference: Hansen and Olsen (1995); Population: 2,041 men with cancer who were diagnosed during 1970–1984 and whose longest work experience occurred at least 10 years before cancer diagnosis. Identified from the Danish Cancer Registry and matched with the Danish Supplementary Pension Fund.; Ascertainment considered complete. Pension record available for 72% of cancer cases.; Outcome definition: Hodgkin disease (ICD-7: 201) listed on Danish Cancer Registry file.; Design: Proportionate incidence study with external comparison group.; Analysis: Standardized proportionate incidence ratio calculated as the proportion of cases for a given cancer in formaldehyde-associated companies relative to the proportion of cases for the same cancer among all employees in Denmark. Adjusted for age and calendar time.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity for NPC (few cases). | Exposure assessment: Individual occupational histories including industry and job title established through company tax records to the national Danish Product Register.; Subjects were considered to be exposed to formaldehyde if: (1) they had worked in an industry known to use more than 1 kg formaldehyde per employee per year and (2) subjects longest single work experience (job) in that industry since 1964 was ≥10 years prior to cancer diagnosis.; All subjects were stratified based on job title as either low exposure (white collar worker), above background exposure (blue collar worker), or unknown (job title unavailable).; Duration and timing: Exposure period not stated. Based on date of diagnosis during 1970–1984, and the requirement of exposure more than 10 years prior to diagnosis, the approximate period was 1960–1974.; Variation in exposure: Not evaluated.; Coexposures: Not evaluated.; [[underlined: As noted in] Appendix B.3.9: While other coexposures were not evaluated, the overall correlation between coexposures in multiple occupational industries is likely to be low.] | External comparisons:; Overall (exposure to formaldehyde ≥10 years prior to cancer diagnosis); SPIR = 1.0 (0.5–1.7) [12]
Reference: Hayes et al. (1990); Population: 4,046 deceased U.S. male embalmers and funeral directors, derived from licensing boards and funeral director associations in 32 states and the District of Columbia who died during 1975–1985. Death certificates obtained for 79% of potential study subjects (n = 6,651) with vital status unknown for 21%.; Outcome definition: Death certificates and licensing boards used to determine cause of death from Hodgkin disease (ICD-8: 201).; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association. | Exposure assessment: Presumed exposure to formaldehyde tissue fixative. Exposure based on occupation, which was confirmed on death certificate. Authors subsequently measured personal embalming exposures ranging from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation) with peaks up to 20 ppm.; Authors state that major exposures are to formaldehyde and possibly glutaraldehyde and phenol.; Duration and timing: Occupational exposure preceding death during 1975–1985. Of 115 deaths from LHP cancer, 66 (57%) were aged 60–74 years. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9:; Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Chemical coexposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; PMR = 0.72 (0.15–2.10) [3]
Reference: Robinson et al. (1987); Population: 2,283 plywood mill workers employed at least one year during 1945–1955 followed for mortality until 1977 with vital status for 98% and death certificates for 97% of deceased.; Outcome definition: Death certificates used to determine UCOD from Hodgkin disease as coded by trained nosologist using ICD-7:201.; Design: Prospective cohort mortality study with external comparison group. A subcohort of 818 men coexposed to formaldehyde and pentachlorophenol were also evaluated.; Analysis: SMRs calculated using sex, age, race, and calendar-year-specific U.S. mortality rates.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde-based glues used to manufacture and patch plywood. Subcohort of 818 men coexposed to formaldehyde and pentachlorophenol worked for one year or more in the relevant exposure categories of veneer pressing and drying, glue mixing, veneer and panel gluing and patching.; Duration and timing: Exposures during 1945–1955. Duration and timing since first exposure were not evaluated.; Variation in exposure:; Duration of exposure; Latency (time since first exposure); Coexposures: Pentachlorophenol; [[underlined: As noted in] Appendix B.3.9: EPA concluded that pentachlorophenol is likely to be carcinogenic based on strong evidence from epidemiological studies of increased risk of multiple myeloma.; Pentachlorophenol is not a known risk factor for Hodgkin lymphoma and thus is not expected to be a confounder.] | External comparisons:; [underlined: Whole cohort of mill workers (n = 2,283)]; SMR = 1.11(0.20–3.50) [2]; [underlined: Subcohort of highly exposed workers (n = 818)]; SMR = 3.33(0.59–10.49) [2]
Reference: Stroup et al. (1986); Population: 2,239 white male members of the American Association of Anatomists from 1888 through 1969 who died during 1925−1979. Death certificates obtained for 91% with 9% lost to follow-up.; Outcome definition: Hodgkin disease (ICD8: 201) listed as cause of death on death certificates.; Design: Cohort mortality study with external comparison group.; Analysis: SMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); High potential for selection bias. Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Confounding possible for ML. Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1925–1979. Median birth year was 1912. By 1979, 33% of anatomists had died. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [As noted in Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.; Anatomists may also be coexposed to stains, [underlined: benzene], toluene xylene, chlorinated hydrocarbons, dioxane, and osmium tetroxide.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.] | External comparisons:; SMR = 0 (0–2.0) [0]
Reference: Walrath and Fraumeni (1984); Population: 1,007 deceased white male embalmers from the California Bureau of Funeral Directing and Embalming who died during 1925–1980. Death certificates obtained for all.; Outcome definition: Hodgkin disease (ICD8: 201) listed as cause of death on death certificates.; Design: Proportionate mortality cohort study with external comparison group.; Analysis: PMRs calculated using sex, race, age, and calendar-year-expected number of deaths from the U.S. population.; [underlined: Confidence in effect estimates:] ^a^; LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; Low sensitivity (few cases). | Exposure assessment: Presumed exposure to formaldehyde tissue fixative.; Duration and timing: Occupational exposure preceding death during 1916–1978. Birth year ranged from 1847 through 1959. Median age of death was 62 years. Most deaths were among embalmers with active licenses. Duration and timing since first exposure were not evaluated.; Variation in exposure: Not evaluated.; Coexposures: None evaluated as potential confounders.; [[underlined: As noted in] Appendix B.3.9: Coexposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and [underlined: ionizing radiation].; Radiation exposure likely to be poorly correlated with formaldehyde so confounding is unlikely.] | External comparisons:; Observed: 0 Hodgkin disease deaths; Expected: 2.5 Hodgkin disease deaths; PMR= 0 (0–1.20)† [0]; †Note: EPA derived CIs using the Mid-P Method (See (Rothman and Boice, 1979))

a Evaluation of sources of bias or study limitations (see details in Appendix B.3.9). SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis. Extent of column shading reflects degree of limitation. Direction of anticipated bias indicated by arrows: “↓” for overall confidence indicates anticipated impact would be likely to be toward the null (i.e., attenuated effect estimate); “↑” for overall confidence indicates anticipated impact would be likely to be away from the null (i.e., spurious or inflated effect estimate).

Abbreviations: SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis; UCOD = underlying cause of death; GSD = geometric standard deviation; SMR = standardized mortality ratio; RR = relative risk; TWA8 = 8-hour time-weighted average; URT = upper respiratory tract; LHP = lymphohematopoietic; PMR = proportionate mortality ratio; OR = odds ratio; SPIR = standardized proportional incidence ratio.

#### Lymphohematopoietic Cancers in Animal Studies

This section considers incidence data for histopathological lesions associated with leukemia or lymphoma; other evidence supportive of the development of these cancers (e.g., hematological changes) is discussed in the Evidence on Mode of Action for Lymphohematopoietic Cancers Section. Few animal bioassays have adequately evaluated the carcinogenic potential of inhaled formaldehyde with respect to LHP malignancies. The majority of formaldehyde exposure studies in animals focused primarily on the respiratory tract and did not provide routine examination of other tissues, limiting the detection of leukemia and lymphoma. The medium confidence study conducted by Battelle-Columbus Laboratories for CIIT (Battelle, 1982) is currently the only chronic duration inhalation study to report detailed information on formaldehyde-induced leukemia or lymphoma in rodents (results not published). Given the paucity of available information and difficulties interpreting the Battelle (Battelle, 1982) results, the evidence available from animal studies is considered indeterminate for drawing conclusions as to whether or not formaldehyde exposure might cause leukemia or lymphoma.

This discussion focuses on the few available studies evaluating tumors of the lympho-hematopoietic system (leukemia and lymphomas), with the evidence organized by species and study confidence (see Table 3-68). The largest and most comprehensive cancer bioassay evaluating formaldehyde inhalation exposure in animals is the medium confidence chronic study (Battelle, 1982) conducted at the Battelle Columbus Laboratory in B6C3F1 mice and F344 rats. This was also the only study to evaluate the majority of tissues relevant to LHP cancers (e.g., no other study reported histopathological evaluation of the spleen or thymus). The summary reports of these experiments in the published literature do not discuss leukemia or lymphoma rates (Swenberg et al., 1980b; Kerns et al., 1983). However, tissue slides were examined histopathologically in all animals from the control and 17.6 mg/m^3^ dose groups at each interim and terminal necropsy; the lesions examined included lymphoma and leukemia (note: increased bone marrow hyperplasia, a nonmalignant lesion that was significantly increased in exposed rats, is also included in Table 3-68 and further discussed in the Evidence on Mode of Action Section). At the intermediate dose groups of 2.5 mg/m^3^ and 6.9 mg/m^3^ exposure concentrations, only the target (i.e., the nasal passages) tissues were examined unless unusual tissue masses or gross lesions were noted, or if the animals died spontaneously, and the study report does not provide incidence at these doses in their summary findings (Battelle, 1982). As stated in the report, survival rates for rats were decreased by formaldehyde exposure at the 17.6 mg/m^3^ exposure for males and females. For the mice, there was no differential mortality across exposure groups; however, there appeared to be decreased survival in all exposure groups after 6 months. The cumulative incidences of lymphoma (in B6C3F1 mice) and leukemia (in F344 rats) as reported by Battelle (see Tables 7–10 in (Battelle, 1982)) are shown in Table 3-67. The p-values reported by the authors were based on a Cox-Tarone test for the comparison that adjusts for reduced survival (Battelle, 1982). There was a suggestion of a possible increased incidence in lymphoma (p-value, 0.06) in female mice, and a decreased incidence in leukemia in female rats (p-value, 0.006) at the high dose. The possible increase in lymphoma incidence in mice is of interest for future study, as low incidences of lymphomas were also observed in two strains of p53 deficient mice after formaldehyde exposure, whereas no lymphomas were observed in control groups [(Morgan et al., 2017); see additional discussion in the Evidence on Mode of Action for Lymphohematopoietic Cancers Section]. It is problematic to infer from these results because of the lack of information at the intermediate dose groups and the adverse effect on survival rates. It is also difficult to interpret the apparent slight increase in lymphoma in mice alongside the slight but statistically significant decrease in leukemia in female rats. Taken together with the exposure-induced increases in bone marrow hyperplasia in rats, this represents an area of uncertainty warranting additional study.

Table 3-67 Cumulative incidence of hematopoietic cancers in B6C3F1 mice and F344 rats

Endpoint, species | Sex | Incidence or percentage incidence | | p-Values
Endpoint, species | Sex | 0 ppm | 17.6 mg/m^3^
Lymphoma, mice | Male | 0/119 (0%) | 0/115 (0%)
| Female | 19/121 (16%) | 27/121 (22%) | 0.062
Leukemia, rats | Male | 11/120 (9%) | 5/120 (4%) | 0.690
| Female | 11/120 (9%) | 7/120 (6%) | 0.006

A separate, medium confidence study in rats did not report any significant differences in histopathological evaluations of tissues relevant to leukemia or lymphoma (Kamata et al., 1997), although specific incidence data for non-nasal lesions were not provided. Although the two other available studies also failed to observe statistically significant, treatment-related increases in LHP cancers in potentially sensitive mice (Morgan et al., 2017) or rats (Sellakumar et al., 1985), these results were interpreted with low confidence due primarily to concerns regarding insensitivity due to a very short exposure duration (8 weeks; (Morgan et al., 2017)), or histopathological evaluations of LHP tissues only when gross lesions were noted (Sellakumar et al., 1985).

Overall, the available data are indeterminate for drawing conclusions regarding the potential for formaldehyde exposure to induce LHP cancers in rodent bioassays. It should be emphasized that the detection of leukemia/lymphoma in the available animal studies (i.e., other than the 0 versus 17.6 mg/m^3^ group comparisons in the Battelle study) may be limited by study design due to limited statistical power, a lack of routine evaluation of tissues potentially related to LHP cancers (studies focused on histopathological evaluation of nasal tissue), or early mortality from toxicities other than LHP cancer, particularly given the few suggestive changes that were reported (i.e., bone marrow hyperplasia in rats and slight but uncertain increases in lymphomas in mice). To make definitive conclusions regarding the development of LHP cancers in formaldehyde-exposed animals, there is a need for studies specifically designed to target these cancers as the main endpoint.

Table 3-68 Summary of animal evidence of lymphohematopoietic cancers and bone marrow histopathology following inhalation exposure to formaldehyde

Reference and study design | Results
Rats
Medium confidence
Kamata et al. (1997); Rats: Fischer 344; male; 32/group; Exposure: nose-only 6 hours/day, 5 days/week for 28 months; interim sacrifices at months 12, 18, and 24; Test article: Formalin (and methanol control); Analytic concentrations: 0, 0.40 (± 0.09), 2.67 (± 0.40), or 18.27 (± 2.73) mg/m^3^. Methanol in the 0 and 18.27 groups was estimated at 5.2 mg/m^3^. A room control served as a no exposure group.; Histopathology: Relevant tissues included mesenteric lymph nodes and femur; and other tissues with noted gross lesions.; Main limitations: Formalin (gaseous methanol levels were not analytically measured in the control and exposed groups, even though a methanol control was included); no histopathological examinations of non-nasal tissues unless gross lesions present; incidence data not reported. | No lesions attributable to formaldehyde exposure were detected in organs other than the nasal cavity.
Kerns et al. (1983), Battelle (1982); Rats: Fischer 344; males and females; 119 to 121/sex/group; Exposure: whole-body 6 hr/d, 5 d/week for up to 24 months; recovery examined at 27 and 30 months; Test article: Paraformaldehyde analytic concentrations: 0, 2.5 (± 0.01), 6.9 (± 0.02), and 17.6 (± 0.05) mg/m^3^; Histopathology: Relevant tissues included femur, mandibular and mesenteric lymph nodes, spleen, and thymus.; Main limitations: Limited evaluation and reporting of LHP cancers, namely no histopathological examinations of non-nasal tissues for 2.5 and 6.9 mg/m^3^ groups (see text) unless gross lesions present; transient viral infection noted at 1 year; high mortality in high exposure group. | Rats, leukemia (all)
| | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| Female | 11/109 (9%) | NA | NA | 7/113 (6%)
| Male | 11/109 (9%) | NA | NA | 5/115 (4%)
| Rats, bone marrow hyperplasia
| | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| Female | 7/106 (6%) | NA | NA | 28/87* (24%)
| Male | 6/108 (5%) | NA | NA | 26/85* (23%)
| NA = Only nasal tissue was systematically analyzed
| *p = 0.0001 (note: see Table 1-64 for leukemia p-values)
| Mortality was significantly higher than controls at 17.6 mg/m^3^ in both sexes and at 6.9 mg/m^3^ in males. This increased mortality began at 12 months and became extreme by 24 months (> 50% in both sexes for the highest exposure group). A transient, commonly observed viral infection was noted at 1 year (not dose-related), along with transient weight decreases.
Low confidence
Sellakumar et al. (1985); Rats: SD; male; 99−100/group; Test article: Paraformaldehyde (slurry in paraffin oil); Exposure: 6 hr/d, 5 d/week for lifetime at 0 or 18.2 mg/m^3^ (note: prior reporting of levels during first 588 days at 17.5 mg/m^3^ (Albert et al., 1982); Histopathology: Histopathology conducted for LHP-relevant tissues (not specified) only when gross lesions were noted; Related study: Albert et al. (1982); Main limitations: LHP tissues were only evaluated if gross lesions were noted. | No differences in tumors outside of the respiratory tract were noted between treated and control groups.
Mice
Medium confidence
Kerns et al. (1983), Battelle (1982); Mice: B6C3F1 mice; males and females; 119 to 121/sex/group; Exposure: whole-body 6 hr/d, 5 d/week for up to 24 months; recovery examined at 27 and 30 months; Test article: Paraformaldehyde; Analytic concentrations: 0, 2.5 (± 0.01), 6.9 (± 0.02), and 17.6 (± 0.05) mg/m^3^; Histopathology: Relevant tissues included femur, mandibular and mesenteric lymph nodes, spleen, and thymus. Note:; Main limitations: Limited sampling and reporting of potential LHP cancers (histopathological examination was carried out only for gross tissue masses at 2.5 and 6.9 mg/m^3^; see text); generally poorer survival of exposed male mice. | Mice, lymphoma (all)
| | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| Female | 19/102 (16%) | NA | NA | 27/121 (22%)
| Male | 0/119 (0%) | NA | NA | 0/115 (0%)
| Mice, lymphoid hyperplasia (mandibular lymph node)
| | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| Female | 19/59 (24%) | NA | NA | 24/63 (28%)
| Male | 7/58 (11%) | NA | NA | 14/49 (22%)
| Mice, lymphoid hyperplasia (spleen)
| | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
| Female | 25/90 (22%) | NA | NA | 22/97 (18%)
| NA = Only nasal tissue was systematically analyzed.
| Generally poorer survival of formaldehyde-exposed male mice (e.g., decreases in survival to at least 18 months were larger at higher exposure levels) was attributed to group housing.
Low confidence
Morgan et al. (2017); Mice: C3B6.129F1-Trp53^tm1Brd^ (C3B6 TP53±) and B6.129-Trp53^tm1Brd^ (B6 TP53±); males; 24–35/group; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hours/day, 5 day/week for 8 weeks.; Test article: Paraformaldehyde; Nominal concentrations were 0, 9.23, or 18.45 mg/m^3^.^a^; Histopathology: Routine evaluations of relevant tissues included frontal plane sections of the femur (including bone marrow), and mesenteric, mandibular, mediastinal, and bronchial lymph nodes. Tissues with gross lesions were also evaluated.; Main limitations: Short duration and short follow-up period to allow for cancer development (note: authors based exposure duration, in part, on HSPC doubling). | The incidences of leukemia or lymphohematopoietic neoplasms were not statistically significantly increased by formaldehyde exposure in either strain.; Lymphomas were observed in several mice exposed to formaldehyde in both strains (i.e., in “B6” mice: 1/31 at 9.23 mg/m^3^ and 1/35 at 18.45 mg/m^3^; in “C3B6” mice: 1/24 at 9.23 mg/m^3^ and 2/25 at 18.45 mg/m^3^), while lymphomas were absent from control groups in both strains (the study authors determined these lesions were unrelated to treatment).

Organized by species, confidence, and then descending publication date. Results from low confidence studies are shaded; these findings are considered less reliable.

Abbreviations: LHP = lymphohematopoietic; FA = formaldehyde-specific antibody; HSPC = hematopoietic stem and progenitor cell.

##### Summary of Animal Evidence Synthesis Judgments

The available animal studies on lymphohematopoietic cancers provide indeterminate evidence of formaldehyde exposure-induced effects. The available animal evidence was judged as indeterminate and not compelling evidence of no effect given the insensitivity of the available study designs for detecting leukemia/lymphoma, particularly given the few suggestive changes that were reported (i.e., bone marrow hyperplasia in rats and slight but uncertain increases in lymphomas in mice). The following factors were most influential to the synthesis judgment.

- Consistency and Study Confidence: The available data do not provide evidence supporting the development of LHP cancers in a medium confidence chronic bioassay of rats and mice, a second medium confidence rat bioassay, and two other low confidence, long-term exposure studies.
- Biological Plausibility: Although some potentially relevant mechanistic changes have been observed in studies of exposed animals (e.g., inflammatory and immune changes in systemic tissues and bone marrow hyperplasia in rats), the evidence related to genotoxicity (i.e., in systemic tissues) or other more directly relevant changes were weak (e.g., only in low confidence studies) or not observed. Further, no potential MOA with evidentiary support exists to explain how inhaled formaldehyde might be capable of inducing these cancers.

#### Evidence on Mode of Action

##### Introduction

This section evaluates evidence supporting plausible mechanisms of LHP carcinogenesis following inhalation exposure to formaldehyde. As previously discussed, the strength of the evidence in humans was determined to be robust for myeloid leukemia and slight for multiple myeloma, although evidence in experimental animals is considered indeterminate. As a mode(s)-of-action has not been established for how formaldehyde inhalation may result in LHP cancers, the available evidence relevant to interpreting the biological plausibility of the observed associations in humans is presented in this section. This discussion includes consideration of how genotoxicity and other potential molecular and cellular events resulting from formaldehyde interactions in upper respiratory tract (URT) tissues might result in LHP cancers. Genotoxicity of formaldehyde in different experimental systems and in human populations is evaluated and described in detail in Appendix A.4; in this section, conclusions from these data are interpreted specifically as pertaining to LHP carcinogenesis. Additional evidence relevant to interpreting the biological plausibility of formaldehyde exposure-induced LHP carcinogenesis has been previously discussed, including DNA damage in peripheral blood cells, impacts on immune cell populations and inflammation in peripheral blood in human populations, systemic oxidative stress, and other health effects outside of the respiratory system, including developmental and reproductive toxicity, hazards for which the evidence indicates that effects in humans are likely. These data are discussed in Sections 3.2.3, 3.2.5, and 3.3.2.

##### Approach: consideration of mechanistic events plausibly relevant to LHP cancer induction following inhaled formaldehyde exposure

This section considers conclusions derived from the analyses of pertinent types of evidence as they relate to LHP cancer (discussed in detail elsewhere in this Toxicological Review), and further examines facets of the genotoxicity database and other mechanistic events specifically relevant to the potential cellular origins of LHP cancer. Rather than a single, linear MOA hypothesis to which formaldehyde-specific data can be applied and evaluated, a network of mechanistic events or pathways may be a more appropriate conceptual framework within which to consider the biological plausibility for many cancers, including LHP carcinogenesis potentially caused by formaldehyde inhalation. These plausible mechanistic events involve specific aspects of genotoxicity and mutagenicity, hematologic effects, and changes in gene expression or regulation, consistent with previous analytical frameworks employed in the evaluation of LHP carcinogenesis (NRC, 2014b). Additionally, this discussion includes consideration of mechanistic effects which have been previously described as hallmarks or enabling characteristics of cancer, as well as key characteristics of carcinogens [e.g., genomic instability and mutation, oxidative stress, inflammation, and avoidance of immune destruction; (Smith et al., 2016; Hanahan and Weinberg, 2011)].

Although there is evidence that exposure to formaldehyde is associated with changes in cell populations that are relevant to LHP cancer mechanisms, a number of studies have demonstrated that direct interactions of formaldehyde with cells in the bone marrow are not likely (see Appendix C.1). In the bone marrow of monkeys (Moeller et al., 2011), and in the bone marrow, liver, lung, spleen, thymus, and blood of rats (Lu et al., 2010a), DNA monoadducts were formed by interactions with endogenous formaldehyde, but adducts formed from exogenous formaldehyde were not found using highly sensitive detection methodology. Recently Lai et al. (2016) described an ultrasensitive mass spectrometry method, which distinguishes unlabeled DPX from ^13^CD_2_-labeled DPXs induced from endogenous and exogenous formaldehyde, respectively. The authors demonstrated that inhalation exposure of stable isotope labeled (^13^CD_2_) formaldehyde to rats (18.45 mg/m^3^; 6 hours/day; 1, 2, or 4 days) and monkeys (7.38 mg/m^3^; 6 hours/day; 2 days) induced DPXs linked to exogenous formaldehyde in nasal passages in both species, but not in distal tissues, such as bone marrow and peripheral blood monocytes (rats and monkeys) and liver (monkeys), although DPXs linked to endogenous formaldehyde were detectable in all tissues. In light of this evidence, in vitro studies of direct administration of formaldehyde to cells from distal tissues, such as bone marrow and blood, were considered less relevant to the evaluation of hazard.).

The approach taken in this section was to identify mechanistic events possibly linking inhaled formaldehyde-induced effects to LHP cancer risk in humans, and then to evaluate the supporting evidence for these events and relationships. The primary focus was on evidence from mechanistic studies of exposed humans where available, incorporating results from in vivo animal studies and in vitro experiments when such information was particularly instructive. The studies most informative to LHP mechanisms were those that examined changes in leukocyte populations or function along with genotoxicity in potential target cells (e.g., hematopoietic stem and progenitor cells [HSPCs], discussed below) or surrogate cell populations (e.g., peripheral blood lymphocytes [PBLs]) from the same human cohorts. Measuring genotoxicity in mature PBLs as surrogates for target cells of concern for LHP carcinogenesis (i.e., HSPCs) is a commonly adopted and reasonable experimental approach (Kirsch-Volders et al., 2014) because PBLs are much more abundant than HSPCs, which constitute only a fraction of a percentage of circulating leukocytes (Massberg et al., 2007; de Kruijf et al., 2014). Other studies selectively reporting hematotoxicity, altered immune function, or genotoxicity in circulating WBCs from formaldehyde-exposed humans or animals also provided useful information.

The mechanistic events specifically evaluated include:

3) Evidence of formaldehyde-induced DNA damage to peripheral blood leukocytes
  a. Genotoxicity in circulating myeloid progenitor cells (possible cancer target population)
  b. Genotoxicity in circulating lymphocytes (surrogate population)
4) Evidence of formaldehyde-induced impacts other than genotoxicity on circulating blood cell populations, including inflammatory changes or immune system dysfunction
5) Evidence of formaldehyde-induced systemic oxidative stress
6) Evidence of formaldehyde-induced changes in the bone marrow niche
7) Evidence of formaldehyde-induced changes in gene expression or posttranscriptional regulation in peripheral blood leukocytes or bone marrow

In each of the following sections, the formaldehyde-specific mechanistic evidence is briefly reviewed, then the relevance to LHP carcinogenesis is described alongside a discussion of the evidence (or lack thereof) addressing how formaldehyde exposure might cause the observed effects.

To frame the discussion of the plausible mechanistic events related to LHP carcinogenesis, relevant elements of HSPC physiology are briefly reviewed. Hematopoietic stem cells (HSCs) are cells residing in the blood or bone marrow that are functionally defined by their ability to replenish their own numbers as well as divide asymmetrically into less plastic progenitor cells. The HSCs reside in localized microenvironments within the bone marrow called “niches,” which control their survival, mobilization, proliferation, self-renewal, and differentiation (Wilson et al., 2009). For example, a single HSC can give rise to common myeloid or lymphoid progenitor cells, which can in turn yield blast cells with dedicated differentiation into specific cell lineages, with a fraction becoming myeloblasts and lymphoblasts, respectively (see Figure 3-42). HSCs and progenitor cells (e.g., myeloblasts, common myeloid or lymphoid progenitors, etc.) are described together as HSPCs (Massberg et al., 2007; Granick et al., 2012) (see Figure 3-42). As previously described (see Section 1.3.3, Overview of Lymphohematopoietic Cancer Biology), LHP cancers are a heterogeneous group. Most LHP cancers, including acute and chronic myeloid leukemias as well as multiple myeloma (i.e., LHP cancers best associated with formaldehyde exposure in epidemiology studies) are thought to arise from damage to HSPCs during hematopoietic and lymphopoietic development, or as a result of environmental exposure, often in a specific HSPC-type and lifestage-dependent manner (Greaves, 2004). However, some LHP cancer subtypes, including CLL and some lymphomas, may arise from mature leukocytes (Eastmond et al., 2014). Thus, this section discusses HSPCs as the most likely proximal target for LHP cancers (i.e., those of primary interest in the context of formaldehyde exposure), while mature leukocytes are discussed as surrogate populations for cancer target cells.

Figure 3-42 Simplified hematopoiesis

Hematopoietic stem cells (HSC) are capable of self-renewal, and can asymmetrically divide to create progenitors committed to either myeloid or lymphoid lineages; together, the HSCs and more committed progenitors comprise hematopoietic stem and progenitor cells (HSPCs; (Massberg et al., 2007; Granick et al., 2012)). The progenitors then supply the precursor cells responsible for maintaining the population of more differentiated cell types within the committed lineage, as depicted. The likely candidate cellular targets for lymphohematopoietic (LHP) cancers are the varied progenitors associated with the monocyte and lymphocyte lineages (a few examples illustrated), as well as HSCs themselves.

##### Evidence of formaldehyde-induced DNA damage to peripheral blood leukocytes

The most pertinent and direct available evidence of formaldehyde-induced effects on target cells relevant to LHP carcinogenesis (i.e., those that may ultimately become neoplastic) is from two studies of the same cohort reporting genotoxicity in myeloid progenitor cells in the peripheral blood of exposed human workers (Appendix C.3). In addition, several studies have been conducted documenting several measures of DNA and chromosomal damage and instability in PBLs of workers exposed to formaldehyde. As these exposures occurred in vivo and the effects are not formaldehyde-specific, no assumptions can be made regarding whether or not formaldehyde must directly interact with the HSPCs or PBLs (e.g., potentially while migrating through URT tissues) to induce the observed changes, or, alternatively, if these represent indirect effects. In vitro formaldehyde exposure of isolated PBLs may also provide some minimal supportive information, although substantially lower confidence exists regarding the relevance of these data, given the limited distribution of inhaled formaldehyde beyond the URT and the assumption that the inhaled formaldehyde concentrations these cells might encounter in URT tissues, if any, would be much lower than the in vitro levels applied. Notably, human PBLs may be less sensitive to potential in vivo genotoxicity compared with HSPCs, as murine HSPCs are more susceptible to aldehyde-induced DNA damage than mature, differentiated leukocytes (Oberbeck et al., 2014; Garaycoechea et al., 2012).

##### Genotoxic effects on circulating myeloid progenitor cells

Among the human occupational studies with formaldehyde exposure, two studies of the same cohort reported effects on myeloid progenitor cells cultured from peripheral blood of exposed workers (Zhang et al., 2010; Lan et al., 2015); (see Appendix C.3) compared to cells cultured from controls without occupational formaldehyde exposure. The specific hematopoietic progenitor cells assessed were identified as CFU-GMs, but not lymphocytes (i.e., myeloblasts in Figure 3-42). CFUs of less committed HSPC colonies (e.g., CFU-GEMMS which can give rise to granulocytes, erythrocytes, macrophages, and megakaryocytes) could not be directly assessed for technical reasons (Zhang et al., 2010; Lan et al., 2015). No information is available to determine if either progenitor cell type would be more or less susceptible to formaldehyde-induced genotoxicity.

In an initial pilot study, increased monosomy of chromosome 7 and trisomy of chromosome 8 was reported in CFU-GMs cultured from a group of 10 highly exposed subjects and 12 controls (8 hour TWA 2.6 versus 0.032 mg/m^3^, respectively) evaluated only for aneuploidy in chromosomes 7 and 8. Decreased WBC counts and a 20% decrease in CFU-GM colony formation was also noted, suggesting hematotoxicity (Zhang et al., 2010). The initial finding of chromosome 7 monosomy was confirmed in a larger, more comprehensive analysis of the same cohort with 29 occupationally exposed subjects and 23 referents (1.7 versus 0.032 mg/m^3^) wherein chromosome-wide aneuploidy and structural aberrations of all 24 chromosomes were examined (Lan et al., 2015). This follow-up study also reported significantly: (a) increased frequencies of monosomy in numerous chromosomes, with the greatest response for chromosomes 1, 5, and 7; (b) increased polysomy in several chromosomes including 1 and 5; and (c) increased tetrasomy in various other chromosomes. In addition to aneuploidy, increased breaks, deletions, and translocations of chromosome 5 were also reported, while trisomy of chromosome 8 was not significantly elevated (Lan et al., 2015). Although the pilot study methods were criticized for not adhering to the assay protocol (Gentry et al., 2013), a clarification of the assay protocol was provided by the investigators with a description of how the study adhered to it (Rothman et al., 2017). Additional findings of monosomy, trisomy, tetrasomy, and structural aberrations of multiple chromosomes that were increased in formaldehyde-exposed workers in comparison to the unexposed referent group indicate that formaldehyde exposure is associated with a potential tendency toward cytotoxicity in CFU-GM cells that may arise either in vivo or during the in vitro cell culture period.

A more recent study in mice from the same researchers similarly suggests that in vivo formaldehyde exposure (3 mg/m^3^ for 2 weeks) might affect the viability of progenitor cells of the granulocyte/monocyte (CFU-GM) or erythroid (BFU-E) lineage based on the ability to generate colonies of these cells in culture (Zhao et al., 2020a). Although they did not specifically examine changes in the blood, the authors reported consistent decrements (across two independent experiments) in BFU-E from the nose; BFU-E and CFU-GM from the bone marrow; and CFU-GM from the spleen. The authors also reported mixed evidence of decrements (across experiments) for CFU-GM from the nose; BFU-E and CFU-GM from the lung; and BFU-E from the spleen. However, the study results cannot be reliably interpreted as clear evidence of formaldehyde-induced effects due to use of formalin as the test article and small sample sizes.

In vitro formaldehyde exposure of cells isolated from healthy, unexposed humans provided mixed results. Formaldehyde exposure-induced aneuploidy in cultured human erythroid progenitor cells (Ji et al., 2014), but not in cultured myeloid progenitor cells (Kuehner et al., 2012). These results suggest either a more complex biological basis for susceptibility to chromosomal damage, or an inability of in vitro test conditions to detect or replicate formaldehyde-associated effects observed in the in vivo studies.

Of interest in the context of susceptibility, in mice, knockout of the genes encoding enzymes responsible for removal of endogenous formaldehyde, namely Aldh2 and Aldh5, results in a phenotype of severely disrupted hematopoiesis and leukemia, including mutated and abnormal HSPCs, which is presumably linked to elevated formaldehyde levels (Pontel et al., 2015; Dingler et al., 2020; Burgos-Barragan et al., 2017b). Likewise, direct treatment of Aldh5-/- bone marrow cells with formaldehdye causes genotoxic effects and reduces HSPC formation, effects which are further exacerbated by loss of Fancd2 (this latter deficiency is associated with increased sensitivity to DNA damage) (García-Calderón et al., 2018; Burgos-Barragan et al., 2017b). As reviewed and tested by Dingler et al. (2020), genetic deficiencies in these Aldh family genes have been linked to bone marrow failure and related diseases in humans, including specifically in children. Other changes in these mouse models and humans with reduced ALDH2 or ALDH5 activity that may be caused, at least in part, by uncontrolled endogenous formaldehyde include postnatal lethality, stunted growth, cognitive effects (see Section 3.3.1) and various cancers arising from DNA damage or deficient repair (Nakamura et al., 2020; Dingler et al., 2020). While formaldehyde inhalation does not seem to cause appreciable changes in formaldehyde levels in nonrespiratory regions (see Appendix A.2), HSPCs expressing these enzymes are known to exist in many tissues. However, no studies in any species have specifically examined these possible linkages in relation to inhaled formaldehyde, limiting the use of the currently available studies in hazard identification to the identification of factors of interest to future studies on susceptibility.

###### Relevance to LHP carcinogenesis and mode of action interpretation

As described above, the cells used in these experiments represent a potential primary target for LHP carcinogenesis. The aneuploidy observed in chromosomes 5 and 7 is of particular relevance for chemically induced LHP carcinogenesis because the loss of whole or part of chromosomes 5 or 7 are common aberrations in therapy-related myelodysplastic syndrome (MDS) and acute myelogenous leukemia (Lessard et al., 2007), particularly those resulting from alkylation drug therapy (Smith et al., 2003; Pedersen-Bjergaard et al., 2006; Lan et al., 2015). Therefore, the observations of similar cytogenetic effects in asymptomatic formaldehyde-exposed workers supports the biological plausibility of the association between chronic formaldehyde exposure and elevated incidence of LHP cancers in other human cohorts (see Section 1.2.5, Evidence on Mode of Action for URT Cancers). Although exogenous formaldehyde may not be transported to or specifically affect the bone marrow in a fashion akin to other well-studied human leukemogens (e.g., benzene, chemotherapeutics, ionizing radiation, (Eastmond et al., 2014)), and may therefore not act via a similar MOA, similar aneuploidies in CFU-GMs from formaldehyde-exposed and benzene-exposed workers have been observed (i.e., monosomy and trisomy in chromosomes 5 and 7; (Zhang et al., 2011). Thus, the presence and type of aneuploidies observed in circulating myeloid progenitor cells from formaldehyde-exposed asymptomatic human workers are consistent with those reported in patients with leukemia, specifically MDS and AML, as well as those effects reported in other worker cohorts at increased risk of developing leukemias, providing further support for the plausibility of an association between chronic formaldehyde exposure and leukemogenesis.

While this evidence links formaldehyde exposure to chromosomal toxicity relevant to leukemogenesis, mechanistic evidence is lacking for how these events may occur. Although no evidence exists to evaluate the following potential scenarios, there are at least three ways in which formaldehyde exposure (with distribution limited to the URT) might cause these genotoxic effects: (1) direct interaction of formaldehyde with HSPCs in the URT; (2) indirect effects on circulating or bone marrow HSPCs due to secondary, systemic effects following formaldehyde-induced changes in the URT; and (3) modification and mobilization of precursor-type cells residing in the URT.

As part of their physiological function, HSPCs migrate via the vasculature to extramedullary tissues (outside medullary bone) such as the liver, lung, small intestine, skin, and kidneys, and return via lymphatics to the bone marrow by a process termed “homing,” which is mediated by cytokines, growth factors, and hormones (Schulz et al., 2009; Massberg et al., 2007; Granick et al., 2012). Although their numbers in the peripheral blood at any one time constitute a small fraction of the total circulating leukocyte population in both mice (Massberg et al., 2007) and humans (Zhang et al., 2010; de Kruijf et al., 2014), these cells can completely replenish bone marrow stem cell populations (Massberg et al., 2007). Unlike mature lymphocytes, HSPCs do not necessarily accumulate in lymphatic tissues (e.g., nasopharynx-associated lymphoid tissue or NALT), but travel primarily through the lymphatic vasculature (Massberg et al., 2007). HSPCs accumulate to some extent in peripheral nonlymphoid tissues and are replenished every few days; alternatively, HSPCs can divide locally and replenish populations of long-lived resident myeloid cells (e.g., macrophages, dendritic cells). In addition to triggering local differentiation, inflammatory stimuli can induce HSPC mobilization from the bone marrow (Wilson et al., 2009), and may increase recruitment of mobilized HSPCs to nonlymphoid epithelial tissues (Massberg et al., 2007). Such inducible migration to and from sites of inflammation (e.g., formaldehyde-induced URT inflammation, see Section 3.2.3) could be a mechanism by which HSPCs become more frequent targets of formaldehyde-induced toxicity. The available data suggest that very little, if any, inhaled formaldehyde penetrates beyond the URT (the portal of entry; POE), although it is likely that small amounts of formaldehyde are able to reach the superficial capillary layer of the URT in some exposure contexts (see Appendix C.1). In addition, whereas formaldehyde appears to preferentially target the respiratory and transitional epithelium of the nasal cavity, it is unclear which specific URT compartments (e.g., respiratory, transitional, or olfactory epithelium; stromal tissue layers) HSPCs may circulate through. Finally, although HSPCs may be more sensitive to genotoxic effects than other cell types, even if inhaled formaldehyde did directly encounter HSPCs, no data exist to draw inferences regarding theoretical concentrations of inhaled formaldehyde that might be required for genotoxicity. Despite these important uncertainties, it is possible that formaldehyde may be able to directly interact with potential target cell types present at the POE.

Alternatively, secondary effects resulting from toxicity, irritation, or other processes disrupted in the affected URT might be capable of causing genotoxicity in HSPCs at sites distal to the URT or in vascular regions proximal to the URT. Such secondary effects might include increased production of mediators of inflammation and oxidative stress, which have been reported after formaldehyde exposure in some studies (see Section 3.2.3), and which may result, indirectly, in cytotoxicity, genotoxicity, or other perturbations at distal sites containing HSPCs, resulting in genotoxicity in these cells. However, no data exist to evaluate this hypothesis, including the potential secondary mediators or what levels of these mediators might be required at target sites.

Lastly, some URT (i.e., rat nasal olfactory epithelium) cells have been shown to be “multipotent” in nature, in that they can repopulate rat hematopoietic tissues and differentiate into various leukocyte lineages in irradiated hosts; although, these cells act more similar to neural stem cells than to bone marrow stem cells (Murrell et al., 2005). While it might be possible that formaldehyde could interact with such a cell population, cause genotoxicity, and modify it in such a way that it becomes more HSPC-like and migrates to the bone marrow, this theory is somewhat implausible and without supportive evidence.

Overall, the evidence largely does not exist to determine whether any of the proposed processes explain how formaldehyde exposure might cause genotoxicity in HSPCs.

##### Genotoxic effects on circulating lymphocytes

Consistent with formaldehyde-induced genotoxicity in circulating myeloid precursor cells, formaldehyde exposure is associated with DNA and chromosomal damage in PBLs (see Appendix C.3 for detailed discussions). The studies in which we had more confidence based on evaluations of study methods reported consistent associations of formaldehyde exposure with DNA strand breaks or alkali-labile sites visualized using the comet assay, CAs, MN formation, and sister chromatid exchange (SCE). Formaldehyde was associated with a higher prevalence of chromosomal aberrations among workers in pathology laboratories (Santovito et al., 2011; Musak et al., 2013; Jakab et al., 2010; Costa et al., 2015); these effects included chromatid-type aberrations, chromosome-type aberrations, chromosomal exchange, and premature centromere division. Costa et al. (2015) also reported an increase in aneuploidies and in the number of aberrant and multiaberrant cells. Micronuclei frequency in PBLs was higher in exposed compared to referent workers by 40–50% with a concentration-related response beginning at concentrations of 0.1–0.2 mg/m^3^ and above (Wang et al., 2019; Jiang et al., 2010; Costa et al., 2019). Micronuclei frequency (and centromeric micronuclei) increased with cumulative exposure (Wang et al., 2019; Suruda et al., 1993). A 1.5 to 3-fold difference in measures of DNA damage using the Comet assay was observed comparing exposed workers to their referent groups at average concentrations as low as 0.09 mg/m^3^ (Zendehdel et al., 2017), 0.14 mg/m^3^ (Jiang et al., 2010) or 0.04−0.11 mg/m^3^ (Peteffi et al., 2015) and a clear concentration-related response was observed in plywood plant workers (Lin et al., 2013; Jiang et al., 2010). Costa et al. (2019) reported that the frequency of micronuclei in PBL and EBC were correlated in their study population. In addition, increased DPXs were observed in circulating WBCs from human workers exposed to formaldehyde concentrations ≥0.5 mg/m^3^. In experimental animals, inhalation studies at relatively high formaldehyde concentrations (i.e., 12.3 and 18.45 mg/m^3^) using paraformaldehyde as the test article have not observed genotoxicity including DNA adducts, chromosome aberrations, or SCEs in PBLs of rats (Lu et al., 2010a; Kligerman et al., 1984). Results of other studies using formalin as the inhalation source were mixed (Speit et al., 2009; Im et al., 2006), although these data are less reliable. While evidence from in vitro formaldehyde exposures is likely of minimal value in relation to LHP carcinogenesis, such evaluations also report increased mutations, DPX, and other DNA damage in human PBLs, whole blood cells or cultured human lymphoblast cell lines (i.e., TK6 cells) (see Appendix C.3).

###### Relevance to LHP carcinogenesis

Genotoxicity in PBLs may reflect formaldehyde-induced effects in HSPCs; because PBLs are more amenable to experimentation, primarily because they are far more abundant, they can allow for far more robust analyses (e.g., in terms of sample size), and possibly better detect changes. Formaldehyde-induced chromosome damage may result from some combination of direct DNA reactivity in the URT, including downstream sequelae, and numerous indirect mechanisms such as deficiencies in DNA repair, chromosome segregation, DNA methylation and increased oxidative stress (see Section 3.2.5 Evidence on MOA; (Kirsch-Volders et al., 2014). Similar to the discussion of the HSPC-specific evidence, direct interactions of formaldehyde with DNA of lymphocytes and less committed progenitor cells could occur in URT tissue regions, although this has not been documented experimentally, or through indirect mechanisms occurring systemically (e.g., as a result of increased oxidative stress). Evidence exists supporting both aneuploidy in PBLs and clastogenicity in URT tissues; notably, the aneuploidy reported in PBLs is consistent with that observed in DNA of CFU-GM cells studied by Zhang et al. (2010) and Lan et al. (2015), and observed in relation to therapy-related MDS and AML as discussed above.

##### Evidence of formaldehyde-induced impacts other than genotoxicity on circulating blood cell populations, including inflammatory changes or immune system dysfunction

A number of studies indicate that formaldehyde exposure causes changes in hematopoietic cell constituents in blood (see Section 3.2.3); however, an understanding of the observed pattern of these changes in specific immune cell subtypes across studies, as well as how any of these changes might be induced, remains incomplete. While there are inconsistencies in the database that introduce uncertainty, the overall evidence supports that it is probable that formaldehyde inhalation causes blood cell changes including decreased total WBCs, CD8 + lymphocytes, and RBCs, particularly at higher formaldehyde concentrations (e.g., ≥1 mg/m^3^; see Section 3.2.3). Relating to formaldehyde-induced decreases in CD8+ lymphocytes, one of the mouse studies discussed in Section 3.2.3 (Ma et al., 2020) provided evidence consistent with the possibility that formaldehyde exposure inhibits commitment to the CD8 lineage at early stages of cell development. Perhaps most relevant to LHP cancers, evidence of pancytopenia (i.e., decrease in RBCs, WBCs, and platelets in the same exposed population) was reported in peripheral blood samples from formaldehyde-melamine workers exposed to median formaldehyde concentrations of 1.6 mg/m^3^, along with a 20% decrease in CFU-GM colony formation in vitro (Zhang et al., 2010), suggesting both a decrease in the circulating numbers of mature RBCs and WBCs as well as possible decreases in the replicative capacity of myeloblasts. This potential for formadehyde to selectively impact immature cells or progenitors is consistent with observations in mice by Liu et al. (2017) and Zhao et al. (2020b), although the use of formalin in these studies prevents reliable interpretation. Perhaps relatedly, a decrease in HSPC colony formation was reported for various CFU populations, including both CFU-GMs and CFU-GEMMs, cultured from human whole blood and exposed in vitro to 100–200 µM formaldehyde (Zhang et al., 2010); however, these experiments carry the same uncertainties as other in vitro assays (see above) including coexposure of the cells to methanol, which prevents reliable interpretation of these findings. In addition, a study of two strains of p53 deficient mice exposed to high levels of formaldehyde (>9 mg/m^3^) for 8 weeks (a duration selected based on the HSPC pool turning over every 8 weeks) did not observe any significant increases in LHP cancers, including leukemia (Morgan et al., 2017). Although studies other than Zhang et al. (2010) do not identify pancytopenia specifically, some report decreases in one or two of these cell types, but not all three (Zhang et al., 2013b; Lyapina et al., 2004; Kuo et al., 1997), or in one or more of these cell populations without examining all three (Ye et al., 2005; Thrasher et al., 1990); while other studies reported no changes or significant increases for specific cell subsets (Erdei et al., 2003; Costa et al., 2013; Aydın et al., 2013), these latter studies tested formaldehyde concentrations of approximately ≤0.36 mg/m^3^. Interestingly, some effects (e.g., changes in T cell populations) tended to increase at lower formaldehyde concentrations (~ <0.5 mg/m^3^), while decreases were observed at higher levels (~1 mg/m^3^). While the data suggest biologic complexity, pancytopenia such as that reported by Zhang et al. (2010), is known to be associated with MDS and AML development (Paiva and Calado, 2014) and may be one of the hematotoxic consequences of exposure to formaldehyde, possibly only at concentrations >1 mg/m^3^.

In an effort to examine potential linkages between effects observed in AML patients and those induced by formaldehyde, several studies have evaluated genotoxicity measures along with immune system effects in the same cohort of occupationally exposed human workers. These studies are considered highly informative to understanding the potential relationship between formaldehyde exposure and systemic toxicity pertaining to LHP carcinogenesis. In several analyses of the same occupationally exposed cohort in China with median exposures of 1.6 mg/m^3^ formaldehyde, lower total peripheral blood cell counts (Zhang et al., 2010; Hosgood et al., 2013), including CTL memory cells, and changes in cytokine levels (Seow et al., 2015) were observed concurrently with genotoxicity in myeloid precursor cells [(Lan et al., 2015) and discussed above]. Findings in this cohort were consistent with findings from Chinese workers and students evaluated by another research group following short-term average formaldehyde exposures of approximately 0.51–0.99 mg/m^3^, which observed decreases in various T lymphocyte populations, including CTLs (Ying et al., 1999; Ye et al., 2005), with a corresponding higher incidence of SCEs in worker lymphocytes at approximately 0.99 mg/m^3^ (Ye et al., 2005). While CTLs were unchanged in several other studies testing lower formaldehyde concentrations (0.2–0.8 mg/m^3^; (Jia et al., 2014; Costa et al., 2013; Aydın et al., 2013), one of these studies did report increased CD4 + T cells alongside evidence of genotoxicity at 0.36 mg/m^3^ (Costa et al., 2013). While CTLs were generally decreased (increasing the ratio of CD4 + T cells to CTLs) in the blood of individuals exposed to formaldehyde concentrations >0.5 mg/m^3^ (see Section 3.2.3), an understanding of how the observed cell number changes might relate to genotoxicity remains unclear.

A reanalysis of data from Zhang et al. (2010) reaffirmed the lower levels of specific immune cell populations, specifically WBCs, lymphocytes, RBCs and platelets in the exposed participants with respect to the unexposed group (Mundt et al., 2017). However, when immune cell population levels were compared within the exposed group using a cutpoint at the median of 1.6 mg/m^3^ (1.3 ppm), no difference was observed between the higher and lower exposed groups. Likewise, no association with formaldehyde modeled as a continuous variable and cell population levels was observed in regression analyses adjusted for sex and smoking. The 43 exposed participants were highly exposed, ranging from a TWA8 of 0.5 to 3.3 mg/m^3^ (0.4 to 2.7 ppm) with one outlier at 6.9 mg/m^3^ (5.6 ppm). Fifty percent of the exposed group was exposed to a TWA8 from 1.1 to 2.5 mg/m^3^ (interquartile range). Therefore, the exposure levels in the study group did not include the breadth of exposure levels needed at lower formaldehyde levels to evaluate an exposure-response trend. The high formaldehyde exposure and the inadequate range of the concentrations limited the power of the study to detect a trend with exposure level of the expected magnitude based on those previously detected for benzene exposure (Rothman et al., 2017).

Changes in serum NK cells and B cells were not entirely consistent across studies, although the available data suggest that formaldehyde concentration may strongly influence the results, similar to findings for CTLs (see Section 3.2.3). For example, while NK cell numbers were decreased at 0.36 and 1.6 mg/m^3^ (Hosgood et al., 2013; Costa et al., 2013) NK cells were actually increased at 0.2 and 0.25 mg/m^3^ (Jia et al., 2014; Aydın et al., 2013) and unchanged at 0.8 mg/m^3^ (Jia et al., 2014). Although changes in B cell counts were supported by moderate evidence across several medium or high confidence studies conducted after several months of exposure, for example at 0.99 mg/m^3^ (Ye et al., 2005) and 0.2–0.8 mg/m^3^ (Jia et al., 2014), other medium or high confidence studies testing formaldehyde exposures for several years, for example at 0.25 mg/m^3^ (Aydın et al., 2013) and 1.6 mg/m^3^ (Hosgood et al., 2013) did not report B cell changes, or reported B cell decreases at lower formaldehyde levels (0.36-0.47 mg/m^3^) (Costa et al., 2013; Costa et al., 2019). Looking across studies, the overall pattern of these responses across exposure levels and exposure durations is difficult to interpret.

Although infrequently studied, some limited mechanistic information suggests the potential for stimulation of the immune system at lower formaldehyde exposures, and decreases in blood cell numbers at higher exposure concentrations. In one study evaluating immunological markers in a cohort of plywood workers, exposure to 0.2–0.8 mg/m^3^ formaldehyde was positively correlated with increased serum interleukin (IL)-10 and IL-4, alongside decreased IL-8 and interferon-gamma (IFN–γ); no significant changes in total lymphocyte or T cell numbers were observed in this study (Jia et al., 2014). These cytokine changes are consistent with observations of increased plasma IL-4 and decreased IFN-γ in a short-term rat study at ≥6.2 mg/m^3^ that reported corresponding lymphocyte genotoxicity (Im et al., 2006). Workers with higher formaldehyde exposure (i.e., 1.8 mg/m^3^) exhibited formaldehyde-associated aneuploidy and had decreased peripheral blood levels of various chemokines and cytokines, including IL-10 (Seow et al., 2015). These observations suggest the possibility of a shift in the functional activation of immune effector cells such as T lymphocytes and macrophages at formaldehyde concentrations below which overt changes in cell number become observable; however, studies specifically testing this possibility have not been performed.

While changes in subpopulations of peripheral leukocytes and circulating levels of cytokines may indicate the potential for some manner of dysfunction in the host immune system, direct observations of dysfunction would be most informative; however, only a few studies specifically examined the potential for events such as immunosuppression in either humans or experimental animals following formaldehyde exposure. In addition, while studies of immune function in the affected airways indicate a probable effect of formaldehyde exposure, studies evaluating immunosuppression at distal sites are inadequate (see Section 3.2.3). In the airways of exposed humans, indirect evidence of decreased immune capacity exists, including decreased resistance to URT infection at 0.9 mg/m^3^ formaldehyde with chronic exposure (Lyapina et al., 2004), and an increased rate of LRT infection in infants exposed to 0.02 mg/m^3^ during their first year of life (Roda et al., 2011). These observations in humans are consistent with the decreased bactericidal activity of leukocytes from the lungs of mice acutely exposed to ≥1 mg/m^3^ formaldehyde (Jakab et al., 1992), and the enhanced malignancy and growth of lung tumors, in association with decreases in NK cell numbers and activity, formed by an injection of syngeneic melanoma cells in mice following exposure to 12 mg/m^3^ (Kim et al., 2013a). Observations related to systemic immune dysfunction, including increased survival to Listeria monocytogenes infections and reduced melanoma tumor mass in B6C3F1 mice (Dean et al., 1984), and increased autoantibodies in exposed adults (Thrasher et al., 1990) are mixed and inconclusive. Thus, while it appears that formaldehyde exposure can suppress immune function in the airways, the pattern of effects across tissue compartments (i.e., URT, LRT, blood and lymphoid tissues) remains unclear.

Together, the evidence supports a decrease in peripheral blood WBC counts in formaldehyde-exposed humans (see Section 3.2.3), although some heterogeneity across studies has been reported in terms of the directionality and magnitude of changes in specific leukocyte subsets and in levels of soluble immunomodulatory molecules (see Section 3.2.3). Considerable heterogeneity has also been observed in relation to the formaldehyde concentration or exposure duration reported for the different observations, further complicating interpretation. Despite this variability, the available data suggest that formaldehyde exposure modifies immune system function across a range of concentrations and durations, with changes in specific leukocyte subpopulations becoming more robust and consistent following exposure to >0.5 mg/m^3^ (see Section 3.2.3).

###### Relevance to LHP carcinogenesis

While many of the changes reported following formaldehyde exposure could create a more permissive environment favoring tumor growth and progression, evidence does not exist to determine whether these changes in immune cell populations or cytokine profiles significantly impact tumor immunosurveillance or cause chronic inflammation; therefore, any specific role for altered immune function in formaldehyde-associated leukemogenesis remains unclear. Changes in immune cell subpopulations, distribution, and activation have a complex relationship with carcinogenesis in terms of tumor suppressing or enhancing activity (Hanahan and Weinberg, 2011). For example, immune suppression is associated with a greater risk of hematopoietic cancers (Bassig et al., 2012), and chronically immunosuppressed human transplant recipients are at increased risk for developing myeloid neoplasms (Morton et al., 2014). Together, this evidence shows that the immune system can operate as a significant barrier to LHP carcinogenesis (Corthay, 2014). In addition, impaired tumor immunosurveillance could result from deficiencies in the development or function of cytotoxic T lymphocytes (CTLs), type 1 T-helper (T_H_1) cells, or NK cells, which might lead to demonstrable increases in tumor incidence (Hanahan and Weinberg, 2011). Conversely, inflammatory immune effector cells (i.e., neutrophils, macrophages, type 2 T-helper [T_H_2] cells, and T and B lymphocytes) can release growth factors and other tolerogenic signaling mediators, which permit tumor growth. The release of reactive oxygen species (ROS) from such cells can be actively mutagenic for nearby cancer cells and accelerate their genetic evolution toward heightened malignancy (Coussens and Werb, 2002). While NK cells play a prominent role in infection and carcinogenesis in the airways (and likely elsewhere in the body), the studies and evidence reporting effects on these cells in any tissue system following formaldehyde exposure are considered weak. Overall, despite the potential for these associations, cell type-specific changes indicative of impaired immunosurveillance or enhanced tumor growth have not been conclusively demonstrated following formaldehyde exposure, particularly at lower levels.

The observed changes in soluble immune factors are similarly difficult to interpret. In addition to the evidence of increased IL-4 in the blood, multiple observations, primarily from allergen sensitization studies in rodents, suggest that IL-4 production in the lower respiratory tract (LRT) in response to antigen stimulation is further exacerbated by formaldehyde exposures ≥0.3 mg/m^3^ (see Sections 3.2.2–3.2.3). Although the specific implications of cytokine changes for tumor development and progression is still emerging, IL-10 and IL-4 in particular are important cytokines in tumor immunology (Li et al., 2009), and the tendency of IL-4 and IL-10 to increase while IFN-γ decreases (see Section 3.2.3) is a pattern commonly observed in human cancer patients, including those diagnosed with some LHP cancer subtypes (Shurin et al., 1999). However, the relationships between cell signaling molecules and affected components of the immune system are complex, and an understanding of how these molecular changes might relate specifically to immune cell dysfunction, and further, to LHP carcinogenesis, is incomplete.

Evidence does not exist to describe how formaldehyde exposure might cause the observed systemic changes in immune system-related responses. While it is possible that these changes might result from disturbed bone marrow hematopoiesis resulting indirectly from formaldehyde exposure, studies specifically testing this possibility were not identified. Alternatively, it is possible that altered immune system responses are related to formaldehyde-induced toxicity at the URT. Interestingly, while peripheral blood CTL levels were generally decreased in individuals exposed to formaldehyde concentrations >0.5 mg/m^3^, respiratory tract CTL levels (and total WBC counts) tended to increase in rodent studies, although the latter data are limited to short-term exposure at much higher formaldehyde levels (see Appendix C.7). It is possible that CTLs were preferentially recruited from the peripheral blood into the URT, thus explaining their depletion from the former and accumulation in the latter tissue; however, none of the identified human studies report WBC counts from both peripheral blood and POE tissue compartments, and the available animal data likewise cannot adequately inform this hypothesis.

Overall, while several studies indicate effects on hematopoietic cell populations and secreted factors, for which exposure concentration may be an important determinant, the impact of these changes on leukemogenesis cannot be clearly discerned.

##### Evidence of formaldehyde-induced oxidative stress

Similar to observations in the airways, inhaled formaldehyde has been associated with biomarkers of oxidative stress in distal tissues (see Section 3.2.3 and Appendix C.7).

Some human studies have evaluated changes in markers of oxidative stress in blood or urine in relation to formaldehyde exposure, and also have attempted to determine whether the oxidation of lipid membrane components might be associated with the presence of formaldehyde-induced DNA damage. Two studies provide evidence of oxidative stress-related genotoxicity or mutagenicity, including elevations in malondialdehyde-deoxyguanosine (M1dG) adducts (i.e., exocyclic DNA adducts formed as byproducts of lipid peroxidation) in WBC DNA with exposure to an average formaldehyde concentration as low as 0.07 mg/m^3^ (Bono et al., 2010). This finding is indirectly supported by an observed association between increases in malondialdehyde and p53 protein (a potential biomarker of carcinogenicity; see discussion of the potential for p53 to contribute to URT carcinogenesis in Section 3.2.5) in plasma with urinary formate levels (which may serve as an imprecise marker of formaldehyde exposure) among cosmetic workers (Attia et al., 2014). Additional evidence that formaldehyde exposure is associated with oxidative stress is provided by a study that reported increased urine levels of 15-F2t isoprostane (a sensitive, but nonspecific marker of oxidative stress) from formaldehyde-exposed workers (Romanazzi et al., 2013); although this marker is not specific to changes in a particular tissue, strong correlations between measurements from urine and plasma (Rodrigo et al., 2007; Morrow et al., 1995) suggest similarly elevated isoprostanes in the workers’ blood. Somewhat in support of the observations in humans, several animal studies in two species observed increases in markers of oxidative stress following acute or short-term formaldehyde exposure to a range of formaldehyde concentrations including ≤1 mg/m^3^; however, these studies had notable methodological limitations, and it is not clear whether these changes persist with long-term exposure (see Section 3.2.3). Suggestive evidence of elevated indicators of formaldehyde-induced oxidative stress and inflammation have been reported in bone marrow from exposed mice at ≥0.5 mg/m^3^ formaldehyde; however, these animals were coexposed to methanol, drawing into question the validity of these findings (formalin was the formaldehyde source; (Zhang et al., 2013b; Yu et al., 2014; Ye et al., 2013b)). These limited studies also observed higher rates of DNA damage in bone marrow. Overall, together with the genotoxicity data, this evidence supports the likely presence of DNA damage and, possibly coincidentally, the likely presence of elevated oxidative stress in circulating leukocytes, although the data are insufficient to describe this potential relationship in terms of duration or concentration of exposure.

Studies of susceptibility to DNA damage conferred by polymorphisms in genes coding for enzymes with activity that either increases or decreases oxidative damage observed greater genotoxicity associated with formaldehyde exposure and polymorphic variation in genes encoding the ROS-inducer, CYP2E1 (more damage associated with wildtype), and the detoxifying enzyme, GSTP1 (more damage associated with variant) (Costa et al., 2015), although another study using a different measure of DNA damage found a marginal increase in susceptibility among exposed with the wildtype GSTP1 allele compared to the variant genotype (Jiang et al., 2010). However, DNA damage in human PBLs was not increased to a greater degree in formaldehyde-exposed human cohorts with increased susceptibility to oxidative damage due to glutathione-S transferase (GSTM1 or GSTT1) null genotype (Santovito et al., 2011; Jiang et al., 2010; Costa et al., 2008); therefore, these results remain inconclusive.

###### Relevance to LHP carcinogenesis

Together, the available data suggest that oxidative stress may be elevated at distal sites following formaldehyde exposure in humans, rats, and mice; however, available studies of genetic susceptibility in exposed workers are not adequate to draw conclusions. Considered alongside the evidence of oxidative stress in the airways (Sections 3.2.1–3.2.2), the data reporting oxidative stress at distal sites suggest that formaldehyde exposure might increase the production of potentially harmful factors throughout the body. If sufficiently severe or sustained for a prolonged duration, oxidative stress could perturb the function of circulating leukocyte populations including HSPCs, increasing lipid, protein, and DNA oxidation, causing DNA strand breakage, as well as altering cellular energetics and signaling pathways (Mikhed et al., 2015). Regarding any potential role in LHP carcinogenesis, the impact of oxidative stress-induced DNA damage on gene or chromosomal changes could be similar to the damage caused by a variety of directly DNA-reactive compounds (Mchale et al., 2012; DeMarini et al., 2000). The available evidence is inadequate to determine what role formaldehyde-associated oxidative stress may play in LHP carcinogenesis, although impacts on leukocyte genotoxicity, increased HSPC mobilization, or immunomodulation are all plausible consequences of systemically elevated oxidative stress.

Data are not available to describe how formaldehyde might cause oxidative stress outside of the airways. Similar to changes in leukocyte cell numbers, this may be secondarily due to sustained airway inflammation, which could cause the release of factors from the inflamed tissue(s) into the circulation that result in increased oxidative stress; however, no studies have examined this possibility. In summary, the potential relationship of increased systemic oxidative stress to LHP carcinogenesis is unknown.

##### Evidence of formaldehyde-induced changes in the bone marrow niche

As noted above, there is some evidence of pancytopenia in formaldehyde-exposed humans that may indicate disturbance of or cytotoxicity in the bone marrow niche at higher environmental exposures. In F344 rats, bone marrow hyperplasia was elevated following chronic exposure to 18 mg/m^3^ formaldehyde (Battelle, 1982). In two chronic rat bioassays (Sellakumar et al., 1985; Kamata et al., 1997) and a short-term (8-week) study of p53 deficient mice (Morgan et al., 2017), the authors evaluating nonrespiratory tissues did not provide details regarding nonneoplastic histopathology in tissues outside the URT, and the incidence of hematopoietic neoplasms did not appear to be elevated in any of these studies. In female B6C3F1 mice exposed similarly to the F344 rats above, hyperplasia was not observed in the bone marrow, spleen or lymph nodes (Battelle, 1982). Evaluations of changes in numbers of bone marrow megakaryocytes were likewise fairly equivocal in mice exposed to 0.5–20 mg/m^3^ formaldehyde (see Appendix C.7).

Two studies in mice suggest that cell subpopulations in the bone marrow niche might be differentially affected by formaldehyde exposure. Specifically, in a 20-week study, a dose-dependent decrease in the ratio of immature to mature RBCs (PCE/NCE ratio) in the bone marrow was observed after exposure to 1 and 10 mg/m^3^ formaldehyde for 2 hours per day (Liu et al., 2017); however, there was no corresponding change in micronucleus rate. A short-term, 2-week study indicated that in vivo formaldehyde exposure of 3 mg/m^3^ caused a decreased formation of BFU-E (erythroid progenitor) and CFU-GM (granulocyte/monocyte progenitor) colonies in cultures from bone marrow or spleen (Zhao et al., 2020b). However, in both of these studies the formaldehyde source is presumed to have been formalin, which prevents interpretation of these results at systemic sites as reliable and highlights this as an area deserving of additional research.

As noted above, a dose-related increase in bone marrow DPXs was observed in BALB/c mice exposed to 0.5–3.0 mg/m^3^ formaldehyde generated from evaporating formalin (Ye et al., 2013a). However, the presence of methanol in the formalin confounds interpretation of the potential for systemic formaldehyde effects, as the co-administered methanol could be rapidly absorbed, distributed to the bone marrow, and locally metabolized to formaldehyde (see Appendix C.1 and C.3). Consistent with this hypothesized contribution of methanol, neither DPXs nor DNA mono adducts were elevated in rodent bone marrow exposed via paraformaldehyde (Lu et al., 2010a; Leng et al., 2019; Heck and Casanova, 2004; Casanova-Schmitz et al., 1984a; Casanova and Heck, 1987). While bone marrow has not been evaluated in exposed human cohorts, elevations in WBC DPX levels have been reported in some human workers chronically exposed to concentrations ≥0.5 mg/m^3^ (Shaham et al., 1997; Shaham et al., 2003), but not consistently in others (Lin et al., 2013).

In general, the data relevant to potential formaldehyde-induced changes in the bone marrow niche were fairly weak and inconsistent across the available studies, although the minimal data available indicate that additional studies are warranted.

###### Relevance to LHP carcinogenesis

Bone marrow niches consist of bone marrow mesenchymal stem cells (BM-MSCs) and HSPC pairings under tight regulation by local input from the surrounding microenvironment, as well as long-distance cues from soluble signaling mediators (e.g., hormones, cytokines, eicosanoids) and the autonomic nervous system (Lo Celso and Scadden, 2011). Aberrant bone marrow stroma can lead to HSPC dysfunction including MDS (Lo Celso and Scadden, 2011), a precursor to AML. Therefore, altered stromal behavior could affect HSPC quiescence and mobilization as well as directly induce the expansion of leukemic clones over normal cells.

Although inhaled formaldehyde does not likely reach the bone marrow to elicit direct effects analogous to exposure in the URT (see Appendix C.1), formaldehyde-induced effects in the URT could indirectly affect the bone marrow microenvironment or “niche” in several ways, including inflammation or induction of systemic immune responses (see Section 3.2.3), oxidative stress (see Sections 3.2.3), hormonal or cytokine changes that affect BM-MSC and HSPC interactions, and disrupted regulation of HSPC mobilization from the niche. However, evaluations of bone marrow following formaldehyde inhalation have been limited to histological or genotoxic endpoints in experimental systems, with no information available regarding either molecular changes in stromal cell function or HSPC activation, differentiation, or mobilization.

The sympathetic nervous system has some control over the mobilization and circulation rate of bone marrow progenitor cells including HSPCs (Elenkov et al., 2000). While formaldehyde exposure has been shown to activate the trigeminal nerve in the rodent URT via transient receptor potential channel stimulation at low concentrations ((Mcnamara et al., 2007); see Section 3.2.1), no studies have examined whether or how this might be indirectly related to regulation of HSPC mobilization or hematopoiesis; however, it is considered unrealistic that activation of neural pathways relaying irritant and pain information would convey excitatory or inhibitory signals to networks responsible for HSPC regulatory functions.

It is difficult to reconcile these disparate observations across the available data streams: the general lack of bone marrow toxicity in experimental model systems corresponds with no excess leukemia reported in chronic rodent bioassays, while the varied fluctuations in immune cell subpopulations, including some evidence of pancytopenia in the peripheral blood of chronically exposed humans (Section 3.2.3), is consistent with the evidence of leukemia induction in humans. It is possible that humans are more sensitive to the hematotoxic effects of formaldehyde than either rodents or nonhuman primates (Goldstein, 2011), as has been noted in the context of chromosomal damage resulting from direct leukemogens (e.g., benzene; (Mchale et al., 2012; IARC, 2012; French et al., 2015)). However, mechanism(s) responsible for any potential differential sensitivity remain to be elucidated. Based on the currently available data, no conclusions can be drawn regarding the potential involvement of formaldehyde exposure-induced indirect effects on the bone marrow niche in LHP carcinogenesis.

##### Evidence of formaldehyde-induced changes in gene expression or posttranscriptional regulation in peripheral blood leukocytes or bone marrow

Few studies have evaluated the effect of formaldehyde exposure on microRNA (miRNA) or messenger RNA (mRNA) levels from non-POE tissues in vivo, and none evaluated chronic exposures. In a small study where human volunteers (N = 21) were variably exposed to ≤1 mg/m^3^ formaldehyde for 5 days, statistically significant changes in mRNA expression were observed in cells from either nasal biopsies or whole blood samples; however, study limitations prevent interpretation of the changes to be a result of formaldehyde exposure (Zeller et al., 2011). In F344 rats, significant changes in both miRNA and mRNA expression were reported in the nasal epithelium and circulating white cells following inhalation exposure to 2.5 mg/m^3^ formaldehyde for ≤4 weeks, primarily involving pathways related to immune/inflammatory response, apoptosis, and proliferation; no significant changes were observed in miRNA samples from the bone marrow, and mRNA transcript levels were not evaluated (Rager et al., 2014). A majority of the reported changes appeared to be tissue- and exposure duration-specific, and only expression of one transcript was consistently affected (miR-326 levels increased) in the WBCs across exposure conditions (Rager et al., 2014). As these endpoints have not been well-studied, conclusions cannot be made regarding the consistency and reproducibility of these data across studies.

###### Relevance to LHP carcinogenesis

Epigenetic mechanisms such as miRNA-mediated regulation of mRNA may play a role in the pathogenesis of LHP malignancies (Yendamuri and Calin, 2009). For example, differential miRNA expression profiles have been reported between normal and leukemia cells, and among LHP cancer subtypes such as AML and ALL (Mi et al., 2007; Marcucci et al., 2009). However, the bone marrow represents a heterogeneous population of cells, and in the context of variable and temporal responses induced following formaldehyde exposure, such gene expression array results can be difficult to assimilate and interpret (Weinberg, 2014).

Although the potential role of miR-326 in LHP carcinogenesis is unknown, increased serum miR-326 expression was associated with bone matrix turnover and positively correlated with lung cancer bone marrow metastasis (Valencia et al., 2013). Considering that WBCs are a highly heterogeneous population, of which only a small fraction is likely to contain target cells of interest in LHP carcinogenesis (i.e., HSPCs), the observation of altered miRNA and mRNA levels in WBCs from rats provides very limited evidence that supports the biological plausibility for other formaldehyde-induced effects, such as genotoxicity (Appendix C.3) in the peripheral blood cells of occupationally exposed humans. Additional studies examining potential epigenetic and transcriptional mechanisms related to LHP carcinogenesis in non-POE tissues following formaldehyde exposure are needed to confirm and expand the observations from this limited set of studies.

##### Discussion of mechanistic evidence relevant to LHP carcinogenesis

While the mechanistic events evaluated in the context of formaldehyde-associated LHP cancer are similar to those described for well-described human leukemogens (Mchale et al., 2012; IARC, 2012), the specific mechanism(s) of LHP cancer induction are not understood, which complicates the construction of any simple, linear MOA (Mchale et al., 2012). Therefore, a network of plausible mechanistic events or pathways was discussed, including specific aspects of genotoxicity and mutagenicity, hematologic effects, oxidative stress, and changes in gene expression or regulation, consistent with previous analytical frameworks employed in the evaluation of LHP carcinogenesis (NRC, 2014b). The most pertinent evidence and conclusions for potential mechanistic events associated with formaldehyde induction of LHP cancers are summarized in Table 3-69.

It is possible that potential LHP target cells (e.g., HSPCs) are affected in the URT tissue, via direct interactions with formaldehyde, given observations that stem cell precursors can traverse between the URT and bone marrow. However, the concentrations of inhaled formaldehyde reaching sites through which HSPCs might traverse (e.g., lymphatic URT tissue), as well as the population of HSPCs present in the URT at any one time, would both be expected to be quite low, although no specific data address these unknowns. Indirect toxicity to HSPCs in the URT also might result from inflammation or oxidative stress in these tissues. Furthermore, genotoxic effects on HSPCs, as well as immune cell toxicity and dysfunction, may occur in peripheral blood or bone marrow via indirect effects of formaldehyde-associated inflammation in the URT resulting in systemic oxidative stress and changes in gene expression or regulation. However, no studies of formaldehyde exposure investigating these hypotheses have been conducted.

Evidence from evaluation of respiratory tract and oral cells (nasal and buccal epithelium), and circulating leukocytes (e.g., HSPCs and PBLs) consistently demonstrates increased levels of Comet assay-detectable DNA damage, as well as MN, CAs, and SCEs associated with formaldehyde exposure from a variety of occupational cohorts. Some of the genotoxic endpoints observed in circulating blood cell progenitors from formaldehyde-exposed workers have also been specifically observed in patients with AML (Mchale et al., 2012; Bowen and Hannigan, 2006), while other endpoints observed in PBLs, such as MN and CA, are generally regarded as biomarkers associated with increased human risk for a variety of cancers, including LHP malignancies (Kirsch-Volders et al., 2014; Fenech et al., 2011; Bonassi et al., 2004b; Bonassi et al., 2007; Bonassi et al., 2008); see Section 3.2.5, Evidence on Mode of Action). Genotoxicity to circulating PBLs may also serve as a surrogate biomarker of genotoxicity in HSPCs, which may play a more direct role in LHP carcinogenesis. No information from the available formaldehyde studies exists to evaluate this potential association.

Following formaldehyde exposure, the available evidence supports the following observations: (a) elevated levels or severity of DNA or chromosomal damage in circulating human blood cells, including in both myeloblasts and mature lymphocyte populations; (b) the specific nature of DNA damage in circulating human leukocytes exhibits aneugenic characteristics similar to damage reported in humans with or at increased risk for AML; and (c) that the human immune system is impacted, possibly as a function of formaldehyde concentration, in a complex manner. Formaldehyde exposure is associated with reductions in immune cell populations, although other lines of evidence indicate stimulation of some immune cell populations, which might reflect a complex concentration or duration dependence in the pattern of effects. The observations of DNA or chromosomal damage in exposed humans, including aneuploidy, and reductions in immune cell populations associated with comparable formaldehyde levels (≥0.5 mg/m^3^) provide coherent evidence suggesting that these effects may be related.

Despite the internal consistency of many of the individual effects described above regarding formaldehyde-induced damage to target cells and biomarkers of genotoxicity in circulating mature PBLs in humans, there is a general lack of understanding regarding both how formaldehyde exposure might cause these changes, as well as how these mechanistic events may lead to LHP cancer. Regarding the latter, for example, any specific effects on the bone marrow niche have not been studied in exposed humans, and the evidence from the available animal studies is generally inconclusive.

The relationships between leukocyte responses in peripheral blood and formaldehyde exposure are complex; studies observed changes in different cell populations, which were both increased and decreased across studies, although some tentative patterns could be discerned, particularly at exposure concentrations >0.5 mg/m^3^. The mechanisms responsible for these observations are unclear, as is any specific contribution of these mechanistic events to LHP carcinogenesis. Likewise, although some evidence exists to support increased systemic oxidative stress associated with formaldehyde exposure, its role in targets of LHP cancers is also unclear, and any specific impacts on immune function or tumor immunosurveillance remain to be determined.

##### Alternative hypotheses

A hypothesized scenario that does not require bone marrow cytotoxicity is that HSPCs damaged in the URT tissues do not return to the bone marrow but form local neoplastic foci. However, there is no evidence supporting this possibility. Collections of neoplastic myeloid cells localized in extramedullary tissues (myeloid or granulocytic sarcomas occurring outside of the medulla of the bone), are associated with MDS and AML but are not commonly reported in human nasal tissue (Yamamoto et al., 2010b; Prades et al., 2002; Paydas et al., 2006). Myeloid sarcomas have not been specifically associated with formaldehyde exposure, although these lesions are frequently misclassified as NHLs in patients without concurrent MDS or AML (Yamamoto et al., 2010a). However, HSPCs do not travel through the nasopharynx-associated lymphoid tissue (Massberg et al., 2007), and may not be the target cell population responsible for nasal myeloid sarcoma. This observation could suggest that the nasal tissue does not provide a suitable niche microenvironment for sustaining neoplastic myeloid cell expansion (Wilson et al., 2009; Granick et al., 2012).

Inferences can be made by extending the proposed hypothesis of circulating or nasal-resident HSPCs as LHP cancer target cells to the spectrum of effects commonly associated with leukemias induced by exposure to other agents (U.S. EPA, 2005a). Although the results of this exercise cannot dismiss the biological plausibility of the events evaluated with specific data from the formaldehyde exposure database, it may illustrate that the identified set of mechanistic events are incomplete. For example, if HSPCs are exposed to the genotoxic activity of formaldehyde as they transit through the URT tissues, and then proceed back to the bone marrow to progressively become leukemogenic, then other genotoxic URT carcinogens could potentially have a similar effect and be associated with both URT and bone marrow cancers. Most agents associated with nasal cancer in humans have not also been associated with leukemia induction, despite displaying variable genotoxic activity, except for those agents that are also systemically available and hematotoxic (IARC, 2012). This suggests that genotoxicity and distribution to the URT alone may not be sufficient to induce LHP carcinogenesis. It has been proposed (IARC, 2012) that well-studied human leukemogens (e.g., ionizing radiation, benzene, chemotherapeutics) induce hematotoxicity more frequently or to a greater extent than neoplasia, which would be consistent with DNA damage more frequently resulting in bone marrow cell death than progenitor transformation. However, this observation cannot rule out leukemogenesis driven by mechanisms other than genotoxicity-induced bone marrow cytotoxicity.

##### Gaps in understanding of formaldehyde exposure-related LHP carcinogenesis

As discussed in this section, there appears to be a lack of concordance between evidence from chronic rodent bioassays and human epidemiological evidence regarding incidence of LHP cancers. Moreover, contrary to the consistent evidence supporting genetic damage to circulating leukocytes in formaldehyde-exposed humans, few positive associations have been reported in rodent bioassays. This MOA discussion evaluated the mechanistic database pertinent to leukemogenesis based on the fundamental assumption that exogenous formaldehyde is not distributed appreciably beyond POE tissues. Differences in physiology between humans and rodents, as well as the apparent relative insensitivity of rodent models to reflect the human pathogenesis of AML (Eastmond, 1997), may together contribute to the potential lack of concordance between the abundant human epidemiological data and the more limited results (e.g., most bioassays did not examine tissues relevant to LHP cancers in detail) from rodent bioassay data.

##### Conclusion

The available evidence supports some events that could contribute to plausible mechanistic pathways relating formaldehyde exposure to LHP carcinogenesis. However, the database was insufficient to support the evaluation or development of any specific MOA. Both temporal and exposure-response relationships have been demonstrated in studies of humans, and mechanistic pathways exist that support a biologically plausible relationship between formaldehyde exposure and cancer, even though the mechanistic pathways explaining such systemic effects are unclear (NRC, 2014b). Most notably, the available evidence for genotoxicity in circulating blood cells is strong and largely consistent. It is important to reemphasize that systemic delivery of formaldehyde is not a prerequisite for the observed mechanistic changes, as some of the reported systemic effects might result from direct interactions with formaldehyde in the URT, while others could plausibly result indirectly from events such as URT irritation, cytotoxicity, oxidative stress, and inflammation locally initiated at the POE. Further, the evidence for other effects at distal sites was compelling. This evidence included increased female reproductive and developmental toxicity and male reproductive toxicity, based on studies of experimental animals and workers exposed to high formaldehyde levels, as well as LRT disease (i.e., current asthma symptoms and decreased asthma control in population-based epidemiology studies). It is plausible that these effects could result indirectly from events occurring in the URT. While the available mechanistic database has limitations, this does not detract from the strength of the association between formaldehyde exposure and myeloid leukemia in epidemiology studies.

##### Summary of Inferences Regarding Mode of Action

###### Support for the hypothesized mode of action in experimental animal models

While evidence for the several identified mechanistic events ranges from strong and consistent to inadequate (see Table 3-69), the supporting evidence was drawn primarily from studies of exposed humans; no single MOA could be assembled and evaluated from the limited relevant experimental animal data available.

###### Relevance of the hypothesized mode of action to humans

Due to the paucity of pertinent mechanistic information, no single, stochastic MOA was identified for LHP cancers associated with formaldehyde exposure. However, evidence supporting the identified mechanistic events was obtained primarily from studies of exposed human cohorts, and thus the mechanistic events are all relevant or of presumed relevance to human LHP cancer risk (see Table 3-69).

Table 3-69 Summary conclusions regarding plausible mechanistic events associated with formaldehyde induction of lymphohematopoietic cancers

Hypothesized mechanistic event | Evidence informing mechanistic event | Human relevance | Weight-of-evidence conclusion and biological plausibility
2.1 Formaldehyde-induced DNA damage to peripheral blood leukocytes | HSPC aneuploidy and structural chromosome damage in myeloid progenitors (CFU-GMs) from human workers occupationally exposed to median levels of 1.6 mg/m^3^ (Zhang et al., 2010; Lan et al., 2015).; - ↑ Monosomy and polysomy in multiple chromosomes (especially monosomy 1, 5, 7) consistent with damage observed in patients with MDS or AML (Lan et al., 2015); - ↑ Breaks, deletions, and translocations in chromosome 5; ↑ genotoxicity in circulating PBLs from inhalation-exposed humans, including increases in strand breaks, MN, CA (see Appendix A.4;)(Kirsch-Volders et al., 2014) NBUDs, or SCE induction at ≥ 0.14 mg/m^3^ (Jiang et al., 2010), and DPXs at higher exposures (Shaham et al., 2003; Lin et al., 2013).; - ↑ DPXs in PBLs from mice after inhalation of formaldehyde generated from formalin (Ye et al., 2013b), although results may be confounded by methanol coexposure; - No increase in DPXs in peripheral blood or bone marrow of monkeys or rats exposed via paraformaldehyde (Lai et al., 2016; Casanova and Heck, 1987); - DNA damage in human PBLs is consistently associated with genotoxicity in human POE tissues (e.g., exfoliated buccal and nasal epithelial cells) in studies evaluating both tissues after longer-term exposures (see Appendix C.3; see Section 3.2.5) | Yes.; Evidence comes primarily from exposed humans. | Strong and consistent human data exist associating formaldehyde exposure with various genotoxic outcomes in myeloid progenitors and PBLs, and exposureresponse relationships demonstrated. Genotoxicity in circulating leukocytes shows concordance with similar endpoints in POE tissues. Aneugenic damage observed in CFU-GMs from formaldehydeexposed human workers is associated with MDS or AML in humans. Together this evidence constitutes the strongest support for the biological plausibility for LHP induction resulting from formaldehyde exposure.
2.2 Evidence of formaldehydeinduced impacts other than genotoxicity on circulating blood cell populations, including inflammatory changes and/or immune system dysfunction | ↓ CFU-GM colony formation in human workers occupationally exposed to median levels 1.6 mg/m^3^ (Zhang et al., 2010), which may reflect not only altered bone marrow progenitor cell viability, but also immune dysfunction or altered activation.; - Numerous published studies reporting divergent changes in various peripheral blood cell populations from formaldehyde-exposed humans (see Section 3.2.3; Appendix C.7), including:; - ↑ Pancytopenia and consistent decreases in total WBCs; ↓ or ↑ in some lymphocyte populations, with decreased CD8 T cells likely at concentration >0.5 mg/m^3^. Fluctuations in immune cell numbers and immune/inflammation markers show a complex pattern with concentration, with decreases in blood cell number and decreased cytotoxic response generally at higher concentrations, some of which are consistent with observations in AML patients (Kim et al., 2015). Other studies indicate immune cell activation generally observed at lower concentrations .0.36 mg/m^3^. | Yes. Most of the available data comes from human studies. | The evidence supporting changes in populations or function of circulating blood leukocytes following human exposure to formaldehyde is strong in terms of a frequency of alterations, but different patterns in changes are reported (e.g., specific direction of changes in various lymphocyte subpopulations, or in blood levels of soluble signaling mediators). LHP cancer risk increases with loss of normal immune function.
2.3 Formaldehydeinduced systemic oxidative stress | - ↑ M1dG adducts in whole blood DNA from pathologists, compared to workers and students in other science labs (Bono et al., 2010), elevated plasma MDA and plasma p53 associated with each other and with urinary formate concentrations (an imprecise marker of formaldehyde exposure) among cosmetics workers (Attia et al., 2014), and ↑ 15-F2t isoprostane levels in the urine of formaldehyde-exposed workers (Romanazzi et al., 2013); - Inconclusive evidence for and against involvement by genes that regulate oxidative stress in formaldehyde associations with DNA damage risk in PBL in humans (see Appendix C.3); - ↓ GSH, ↑ ROS, ↑ MDA in bone marrow, peripheral blood mononuclear cells, liver, spleen, and testes (Ye et al., 2013b), although markers of oxidative stress were not correlated with DPXs and results may be confounded by methanol coexposure. | Yes. Some human data available, and results from experimental models are presumed relevant to humans. | Limited human and rodent evidence supports the association between formaldehyde exposure and induction of oxidative stress beyond the POE. While biologically plausible, the available evidence is inadequate to determine what role such oxidative stress may play in LHP carcinogenesis.
2.4 Formaldehydeinduced changes in the bone marrow niche | - ↑ Bone marrow hyperplasia in rats from one study (Kerns et al., 1983; Battelle, 1981), but unclear if other results were negative or null (Sellakumar et al., 1985; Kamata et al., 1997) due to imprecise reporting; - Dose-related ↑ DPXs in the bone marrow of formalinexposed mice (Ye et al., 2013b), although results may be confounded by methanol coexposure; - HSPC mobilization and the BM-MSC niche is regulated by cytokines, hormones, and signals, which may be distributed through circulation as a result of inflammation although these effects have not been directly evaluated following formaldehyde exposure | Yes. Available data are from experimental models presumed relevant to humans. | The limited evidence available is currently inadequate to evaluate any effect on bone marrow or stromal cells following formaldehyde exposure, although such an effect appears consistent with current understanding of hematopoiesis.
2.5 Evidence of formaldehydeinduced changes in gene expression or posttranscriptional regulation in peripheral blood leukocytes or bone marrow | Limited study reported some statistically significant differences in mRNA expression in either nasal or whole blood samples from human volunteers associated with 5-day exposures up to 1 mg/m^3^ formaldehyde; however, study limitations prevent interpretation that results were related to formaldehyde exposure (Zeller et al., 2011). In F344 rats, significant changes in both miRNA and mRNA expression were reported in the nasal epithelium and circulating WBCs following inhalation exposure to 2.5 mg/m^3^ formaldehyde for 1 or 4 weeks; no changes were observed in miRNA expression in the bone marrow, and mRNA was not evaluated (Rager et al., 2014).; - “Immune system/inflammation” markers were enriched in both nasal tissue and WBCs at both time points; - ↑ WBC miR-326 expression, associated with bone marrow metastasis in other models (Valencia et al., 2013) | Yes. Available data are from experimental models presumed relevant to humans. | Limited rodent evidence supports the association between formaldehyde exposure and epigenetic effects in circulating leukocytes; the available human evidence is inadequate. Insufficient evidence is available to determine what role epigenetics may play in LHP carcinogenesis.

Abbreviations: HSPC = hematopoietic stem and progenitor cell; MN = micronuclei; CA = chromosomal aberration; CFUGM = colony-forming unit, granulocytes and macrophages; MDS = myelodysplastic syndrome; AML = acute myeloid leukemia; PBL = peripheral blood lymphocytes; NBUD = nuclear budding; SCE = sister chromatid exchange; DPX = DNA-protein crosslink; GSH = glutathione; ROS = reactive oxygen species; MDA = malondialdehyde.

#### Evidence Integration Summary

The strength of the evidence from human studies is robust for myeloid leukemia (see Lymphohematopoietic cancers in humans above). The assessment of LHP cancers was based on epidemiology studies of groups with occupational formaldehyde levels either in specific work settings (e.g., cohort studies) or in case-control studies. Aneuploidy in chromosomes 1, 5, and 7 in circulating myeloid progenitor cells, considered a potential primary target for LHP carcinogenesis was associated with occupational formaldehyde exposure. The type of aneuploidies observed in the formaldehyde-exposed asymptomatic human workers are also found in patients with leukemia, specifically MDS and AML, as well as other worker cohorts at increased risk of developing leukemias, which provides support for the plausibility of an association between chronic formaldehyde exposure and leukemogenesis. Moreover, the strong and consistent evidence from a large set of studies that observed mutagenicity in circulating leukocytes of formaldehyde-exposed humans, specifically CAs, and MN formation, provides additional evidence of biological plausibility for these cancer types. Further support is provided by studies that observed perturbations to immune cell populations in peripheral blood associated with formaldehyde exposure. In particular, decreases in RBCs, WBCs, and platelets, along with a 20% decrease in CFU-GM colony formation in vitro were observed in the same exposed group (Zhang et al., 2010), suggesting both a decrease in the circulating numbers of mature RBCs and WBCs as well as possible decreases in the replicative capacity of myeloblasts.

Increased LHP cancers have not been observed in a large, medium confidence, chronic rodent bioassay involving inhalation exposure of both rats and mice to formaldehyde, although routine histopathological evaluations were only performed at the highest exposure level (which caused high mortality in rats), nor in another medium confidence rat bioassay that failed to report the incidence of non-nasal neoplastic lesions. However, there are notable uncertainties in the available animal data, including increased bone marrow hyperplasia in rats, slight but uncertain increases in lymphoma in mice, and a general lack of rigorous evaluation of non-respiratory tissues. Mechanistic changes related to leukemia have not been consistently reported in well-conducted rodent studies. Thus, while uncertain and insufficient to inform the hazard judgment in either direction, there is a general lack of clear support for the human epidemiological evidence from rodent bioassays, noting that concordance across species is not necessarily expected (U.S. EPA, 2005a). The apparent lack of consistency in results raises uncertainties about the currently available research results on these diseases, including how formaldehyde exposure-induced LHP cancers might arise without substantial distribution to target sites. Notably, it is important to emphasize that the available animal evidence was judged as indeterminate and not compelling evidence of no effect (see evidence integration methods in Section 2.6), as there are important uncertainties that prevent such an interpretation. Thus, the animal evidence does not detract from the strength of the association between formaldehyde exposure and myeloid leukemia (and related mechanistic changes) in epidemiology studies (NRC, 2014b). Differences in physiology between humans and rodents, as well as the apparent relative insensitivity of rodent models to reflect the human pathogenesis of AML (Eastmond, 1997), may together contribute to the potential lack of concordance between the abundant human epidemiological data and the more limited results (e.g., most bioassays did not examine tissues relevant to LHP cancers in detail) from rodent bioassay data.

Taken together, based on the robust human evidence from studies of groups with occupational formaldehyde levels, the evidence demonstrates that formaldehyde inhalation causes myeloid leukemia in humans (see Table 3-70). Separately, based on a limited number of epidemiological studies and potentially relevant mechanistic evidence in exposed humans, the integration of the evidence results in a judgment that the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma and Hodgkin lymphoma. While mechanisms for the induction of myeloid leukemia are yet to be elucidated, they do not appear to require direct interactions between formaldehyde and bone marrow constituents, and either are different in animals or the existing animal models tested thus far do not characterize the complex process leading to cancers in exposed humans.

Table 3-70 Evidence integration summary for effects of formaldehyde inhalation on LHP cancers

Evidence | Factor | Increasing Certainty | Decreasing Certainty | Synthesis Judgment | Hazard determination
Myeloid Leukemia
Human | Consistency and Study Confidence | - Consistent increases in risk across a set of high and medium confidence, independent studies with varied study designs and populations. | | Robust; Based on consistent findings of increased risk in high and medium confidence studies of groups exposed to occupational formaldehyde levels, several of which demonstrated large and dose-dependent elevations. Although not necessary for this judgment, the strong and consistent evidence from a large set of studies that observed mutagenicity in circulating leukocytes of formaldehyde-exposed humans further supports the plausibility of the cancer findings. | The evidence demonstrates that formaldehyde inhalation causes myeloid leukemia in humans; This conclusion was primarily based on epidemiology studies of groups with occupational formaldehyde exposure. While evidence exists to suggest a lack of concordance between chronic rodent bioassays and human epidemiological evidence, notable uncertainties prevent an animal evidence judgment of compelling evidence of no effect; Potential susceptibilities: There is no evidence to evaluate the potential risk to sensitive populations or lifestages
Human | Strength and Precision | - Several studies demonstrated strong associations (1.5- to 3-fold increase in risk)
Human | Dose-Response | - Several studies demonstrated clear exposure-response relationships across multiple measures of increasing exposure
Human | Coherence | - A temporal relationship consistent with causality (i.e., allowing for cancer induction, latency and mortality)
Human | Biological Plausibility | - Evidence from high and medium confidence studies of exposed humans identifies relevant mechanistic changes for cancers of the blood such as myeloid leukemia, including impacts on peripheral immune cell populations (which seem to be affected in a complex manner), and elevated levels or severity of DNA or chromosomal damage in circulating myeloblasts and mature lymphocyte populations. The DNA damage exhibits aneugenic characteristics similar to that found in humans with, or at increased risk for, acute myeloid leukemia.; (Note: potentially relevant to cancer types below)
Animal | Consistency and Study Confidence | | - Overall, the available data do not provide evidence supporting the development of LHP cancers in a medium confidence chronic bioassay of rats and mice, a second medium confidence rat bioassay, and two other low confidence, long-term exposure studies. | Indeterminate (for any LHP cancer type) Based on the general lack of relevant cancers in two well-conducted studies and the lack of strong evidence supporting biological plausibility. Uncertainties in the available studies prevent a judgment of compelling evidence of no effect.
Animal | Strength and Precision | N/A
Animal | Dose-Response | N/A
Animal | Coherence | N/A
Animal | Biological Plausibility | Although some potentially relevant changes have been observed in mechanistic studies of exposed animals (e.g., inflammatory and immune changes in systemic tissues and bone marrow hyperplasia in rats), the evidence related to genotoxicity (i.e., in systemic tissues) or other more directly relevant changes were weak (e.g., only in low confidence studies) or not observed. Given the MOA inference (below), the mechanistic data do not suggest a judgment other than indeterminate for LHP cancers in animals.
Other inferences | - Relevance to humans: The evidence is from studies in humans.; - MOA: No MOA exists to explain how formaldehyde might cause LHP cancers without systemic distribution (i.e., without direct interactions of inhaled formaldehyde with constituents in bone marrow tissue); however, given the mechanistic changes in exposed humans, it is reasonable to infer that an undefined MOA is likely to involve modulatory effects on circulating immune cells.
Multiple myeloma
Human | Consistency and Study Confidence | - Increases in risk associated with peak exposure metrics across one high, one medium, and two low confidence studies. | - No associations with exposure metrics other than peak. | Slight; Based primarily on increased risks with peak exposure in two well-conducted studies, with some mechanistic support (see description for myeloid leukemia). | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Human | Strength and Precision | - Increases spanned an approximate 1.2- to 4fold increase in risk, with the highest confidence evidence showing a 2-fold increase. | - Risks may have been driven by peak exposures as increases were limited to groups of people who experienced high peak exposures, and two low confidence studies reported inverse relationships with duration of exposure. | Slight; Based primarily on increased risks with peak exposure in two well-conducted studies, with some mechanistic support (see description for myeloid leukemia). | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Human | Dose-Response | - Very limited evidence of an exposure-response relationship in one high confidence study | | Slight; Based primarily on increased risks with peak exposure in two well-conducted studies, with some mechanistic support (see description for myeloid leukemia). | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Human | Coherence | N/A | | Slight; Based primarily on increased risks with peak exposure in two well-conducted studies, with some mechanistic support (see description for myeloid leukemia). | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Human | Biological Plausibility | [Description above for myeloid leukemia applies to human evidence for all LHP cancers] | | Slight; Based primarily on increased risks with peak exposure in two well-conducted studies, with some mechanistic support (see description for myeloid leukemia). | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Animal | Consistency and Study Confidence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type) [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Animal | Strength and Precision | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type) [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Animal | Dose-Response | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type) [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Animal | Coherence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type) [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Animal | Biological Plausibility | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type) [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Other inferences | - Relevance of the animal evidence to humans: The evidence is from studies in humans.; - MOA: No MOA exists to explain how formaldehyde might cause LHP cancers without systemic distribution. | | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause multiple myeloma^a^
Hodgkin lymphoma
Human | Consistency and Study Confidence | - Significantly increased risk in the highest peak exposure group alongside an exposure-response relationship in one medium confidence study of industrial workers. | - An inconsistent pattern of risks across 1 medium and the low confidence studies, many with <5 exposed cases, noting that the high survival rate for Hodgkin lymphoma may indicate that mortality data are not a good proxy for incidence. | Slight; Based primarily on suggestive findings from a single study in the absence of clearly conflicting evidence. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Human | Strength and Precision | N/A | | Slight; Based primarily on suggestive findings from a single study in the absence of clearly conflicting evidence. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Human | Dose-Response | N/A | | Slight; Based primarily on suggestive findings from a single study in the absence of clearly conflicting evidence. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Human | Coherence | N/A | | Slight; Based primarily on suggestive findings from a single study in the absence of clearly conflicting evidence. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Human | Biological Plausibility | [Description above for myeloid leukemia applies to human evidence for all LHP cancers] | | Slight; Based primarily on suggestive findings from a single study in the absence of clearly conflicting evidence. | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Animal | Consistency and Study Confidence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type); [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Animal | Strength and Precision | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type); [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Animal | Dose-Response | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type); [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Animal | Coherence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type); [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Animal | Biological Plausibility | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate (for any LHP cancer type); [see above explanation] | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Other inferences | - Relevance to humans: The evidence is from studies in humans.; - MOA: No MOA exists to explain how formaldehyde might cause LHP cancers without systemic distribution | | | | The evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause Hodgkin lymphoma^a^
Lymphatic leukemia
Human | Consistency and Study Confidence | | - A consistent pattern of null results across eight high, medium, and low confidence studies, noting that the high survival rate for lymphatic leukemia may indicate that mortality data are not a good proxy for incidence. | Indeterminate; Based on a general lack of associations for this cancer type. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Human | Strength and Precision | N/A | | Indeterminate; Based on a general lack of associations for this cancer type. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Human | Dose-Response | N/A | | Indeterminate; Based on a general lack of associations for this cancer type. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Human | Coherence | N/A | | Indeterminate; Based on a general lack of associations for this cancer type. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Human | Biological Plausibility | [Description above for myeloid leukemia applies to human evidence for all LHP cancers] | | Indeterminate; Based on a general lack of associations for this cancer type. | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Animal | Consistency and Study Confidence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate,; [see above explanation] | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Animal | Strength and Precision | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate,; [see above explanation] | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Animal | Dose-Response | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate,; [see above explanation] | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Animal | Coherence | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate,; [see above explanation] | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Animal | Biological Plausibility | [Description above for myeloid leukemia applies to all LHP cancers] | | Indeterminate,; [see above explanation] | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans
Other inferences | N/A: no signal exists across lines of evidence | | | | There is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing lymphatic leukemia in humans

N/A = indicates the factor was not applicable to (i.e., did not influence) the judgment drawn

a Given the uncertainty in this judgment and the available evidence, this assessment does not attempt to define a quantitative estimate for this cancer type (see Section 5.2).

16 For example, although only indirectly applicable to formaldehyde exposure-induced sensory irritation, dry eye disease is far more prevalent in older individuals (age 50+) than younger individuals (under 18) (Farrand et al., 2017). This is based, at least in part, on differences in tissue physiology that help regulate access of airborne irritants to sensitive components of the eye (e.g., reduced tear production and changes in lipid composition with aging). While this may also apply to the direct irritant effects of airborne formaldehyde on the eye, it is unclear the extent to which parallel, protective, age-dependent mechanisms exist within the nasal epithelium.

17 Note: neural reflexes involving afferent and efferent activity of the vagus nerve (e.g., across different LRT regions), some of which may involve C fibers and TRP channels, are better established (Mazzone and Undem, 2016).

18 Hyperresponsive airways (or hyperresponsiveness) represents a mechanistic event (supported by robust evidence) and a potential key feature of respiratory health hazards that is defined to encompass any of a range of relevant airway features, including hyperreactivity (exaggerated response) and hypersensitivity (lower dose to elicit response). See also Appendix C.7.

19 Only one incidence study was found in the literature search (Smedje and Norback, 2001); this study was classified as a low confidence study because only two formaldehyde measures were taken over the four-year period, and 2/3 of the students left the school before the follow-up evaluation which added to the uncertainty in the relevance of the exposure measure. The evidence from this study was not considered in the synthesis; the study details are presented in Table 3-14 and characterized as a low confidence study.

20 Note: Swiecichowski et al. (1993) and Leikauf (1992) are interpreted to use the same cohort of animals.

21 As the challenge stimuli used in the formaldehyde studies included allergens as well as nonimmunological stimuli, and because most experiments did not attempt to delineate the specifics of the functional changes, “airway hyperresponsiveness” or “hyperresponsive airways” encompasses any of a range of possible airway features: hyperreactivity (exaggerated response), hypersensitivity (lower dose to elicit response), altered ventilatory parameters (e.g., maximal response, resistance), recovery (longevity of response), or others.

22 Values of n for 11 local irritants as estimated by ten Berge et al. (1986) averaged 1.9 (range 1.0−3.5), while 21 local irritants relying on data in rats or mice, as summarized in Appendix G by California EPA (OEHHA, 2008), averaged 1.8 (range 0.5−4.0). Of potential interest to this assessment, the chemicals included ammonia (n = 2.0) and acrolein (n = 1.2).

23 Lesion frequency or severity in the study by NTP (2017 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=4532294)) was not noticably different from the other available studies of wild-type mice similarly exposed to >9 mg/m^3^ (i.e., 12.4 and 17.6 mg/m^3^) for subchronic [e.g., (Maronpot et al., 1986)] or chronic [e.g., (Kerns et al., 1983)] duration.

24 For Andjelkovich et al. (1995), assuming a rate of NPC for U.S. workers of 0.6 per 100,000 person-years (Curado et al., 2007), the expected number of cases would have been 0.33 and the ^~^SMR = 0 (95% CI 0, 5.99).

25 For Edling et al. (1987b), assuming a rate of NPC for Swedish workers of 0.4 per 100,000 person-years (Curado et al., 2007), the expected number of cases would have been 0.028 and the ^~^SMR = 35.71 (95% CI 1.79, 176.1).

26 For comparison, the background incidence rate in the United States is 0.6 cases per year for each 100,000 people and ranges from 3.5 to 17.8 cases per year for each 100,000 people in the Philippines, Taiwan, and Hong Kong (see Table 3-31).

27 Möhner et al. (2019) argued that there might have been a diagnostic bias in coding the specific and non-specific pharyngeal cancer in the NCI cohort study which could have affected the pharyngeal cancer SMRs; however, potential administrative miscoding of cancer mortality on death certificates would be independent of the quantitative estimates of workers’ exposures, and any misclassification of diagnostic codes would not be expected to yield evidence of exposure-response relationships.

28 Note the pooled study by Luce et al. (2002) includes data from 12 publications and thus represents substantially more information than a single result. The references for the source data are: Zheng et al. (1992); Vaughan et al. (1986a, 1986b); Vaughan (1989); Vaughan and Davis (1991); Merler et al. (1986); Magnani et al. (1993); Luce et al. (1992); Luce et al. (1993); Leclerc et al. (1994); Hayes et al. (1986b); Hayes et al. (1986a); Hardell et al. (1982); Comba et al. (1992a); Comba et al. (1992b); Bolm-Audorff et al. (1990); Mack and Preston-Martin (Unpub. Data presented in Luce et al. (2002)); Brinton et al. (1984); Brinton et al. (1985).

29 For Andjelkovich et al. (1995), assuming a rate of SNC for U.S. workers of 0.6 per 100,000 person-years (Curado et al., 2007), the expected number of cases would have been 0.33 and the ^~^SMR = 0 (95% CI 0, 5.99).

30 Conolly et al. (2003) modeled the dose-response for squamous cell carcinoma (SCC) data by combining the data from Kerns et al. (1983) and Monticello et al. (1996) and the data from these 94 rats. The individual animal data pertaining to the combined data are reported in the Appendix in Conolly et al. (2003). EPA’s dose-response analysis used the combined data.

31 In fact, studies of subchronic formaldehyde exposure without follow-up consistently failed to observe dysplasia or neoplasms in the nose, trachea, larynx, or lungs across a range of formaldehyde concentrations in rats (Zwart et al., 1988; Woutersen et al., 1987; Wilmer et al., 1989; Rusch et al., 1983; Feron et al., 1988; Appelman et al., 1988) and mice (Maronpot et al., 1986), and at lower formaldehyde levels (<3.65 mg/m^3^) in hamsters and cynomolgus monkeys (Rusch et al., 1983). Studies with a long observation period were not identified to inform the possibility of cancer development in nonhuman primates exposed to formaldehyde.

32 While some data exist to suggest that SCCs can be induced following subchronic formaldehyde exposure when observations continue for more than 2 years (Woutersen et al., 1989; Feron et al., 1988), definitive experiments in rats that are sensitive to the development of SCCs have not been performed (e.g., comparing SCC incidence in Sprague Dawley or F344 rats exposed for shorter durations and followed up for >2 years versus rats exposed to the same concentrations for >2 years with no additional follow up).

33 In addition, a single, cursory animal experiment on nociception was identified; this evidence was considered indeterminate.

34 The capacity to conceive and deliver a baby.

35 Fecundability is the probability of a couple conceiving in 1 month, calculated as the average number of menstrual cycles to achieve a pregnancy for a group divided by the total number of cycles experienced in the group.

36 Unlike the available database for nasopharyngeal cancer, the background incidence rates for myeloid leukemia in the 10 study populations were less variable: Six populations were from the U.S., and there was one each from England, Finland, Italy, and Europe. The Age-standardized (world) incidence rate of myeloid leukemia in the U.S. was 4.8 per 100,000 people per year [SEER: 14 registries], the rates in England ranged from 3.4 to 4.0 per 100,000 people per year [Eight locations], the rate in Finland was 3.2 per 100,000 people per year, the rate in Italy ranged from 2.5 to 6.9 per 100,000 people per year [22 locations], based on the IARC publication Cancer Incidence in Five Continents (Curado et al., 2007). Rates for Europe, as a unit, were not specified in this source.

37 In Beane Freeman et al. (2009), for peak exposure there were four cases of ML who were unexposed, 14 cases with peak exposure from >0 to <2 ppm, 11 cases with peak exposure from 2 to <4 ppm, and 19 cases with peak exposure ≥4 ppm. In Checkoway et al. (2015), the new definition of peak exposure and the recategorization resulted in 27 cases of ML with peak exposures from 0 to <2 ppm, 11 cases with peak exposure from 2 to <4 ppm, and 10 cases with peak exposure ≥4 ppm. The Checkoway et al. (2015) results were classified with low confidence due to information bias and low sensitivity.

38 Based on six paired effect estimates from Hauptmann et al. (2009), five paired estimates from Meyers et al. (2013), two paired effect estimates from Checkoway et al. (2015) and one pair of effect estimates from Saberi Hosnijeh et al. (2013).