# 2 ASSESSMENT METHODS

This chapter describes the underlying framework, organization, and methods used to conduct the systematic reviews included in this assessment. The evaluation of formaldehyde’s toxicity was informed by what is known about the toxicokinetics of inhaled formaldehyde (see Section 3.1 and Appendix C.1), and this knowledge is reflected in the organization of the Hazard Identification section. These Assessment Methods outline the approaches implemented throughout different stages in the assessment development, which can be grouped into those used to (1) identify and evaluate individual studies (Sections 2.2 and 2.3); (2) summarize, synthesize and integrate the evidence, including interpreting the support for particular human health effects across different streams of evidence (i.e., human, animal, and mechanistic studies) and developing summary conclusions (Sections 2.4, 2.5 and 2.6); and (3) select and analyze studies and data to derive quantitative (dose-response) values (Section 2.7). The process for hazard identification, which involves hazard-specific literature searches, outcome/endpoint-specific evaluation of study methods, synthesis of information within each stream of evidence, and integration across streams of evidence, is displayed in Figure 2-1. The process involves a successive focusing on the more informative outcomes/endpoints within each hazard domain and the most methodologically sound studies.

The methods applied are described here, while the documentation (e.g., the results of literature search and screening and study evaluations) is provided in the Appendices. Literature search and screening and study evaluations are documented in Appendix B.2 and B.3, respectively.

Figure 2-1 Overview of assessment methods for hazard identification

This figure illustrates the flow of evidence through the assessment, sequentially focusing on the most useful information, as well as the decision-making processes for arriving at evidence judgments regarding the potential for noncancer health effects and for specific types of cancer. Mechanistic inference considered during evidence integration included biological plausibility or relevance of animal study results to humans and identification of susceptible groups. Notes: Given this assessment’s framing around prior reviews of formaldehyde’s potential toxicity (i.e., health effect-specific searches guide this review), for this assessment, the synthesis judgment of “compelling evidence of no effect” and the integration judgment of “strong evidence of no effect” were not reached for any of the evaluations; as such, criteria for these categories are not applied in this assessment. Importantly, hazard identification for carcinogenicity includes an additional step of assigning a descriptor regarding the potential for formaldehyde to cause cancer (this step is not shown but is discussed in this section below).

Abbreviations: HERO = Health and Environmental Research Online; PECO = Populations, Exposures, Comparators, Outcomes; ADME = absorption, distribution, metabolism, excretion; MOA = mode of action.

## 2.1 ASSESSMENT ORGANIZATION AND DOCUMENT MAP

The Toxicological Review critically reviews the publicly available studies relevant to human health hazards that may result from formaldehyde inhalation and describes the level of certainty in the supporting evidence. When there was sufficient certainty in the evidence supporting a hazard and appropriate studies and data were available, toxicity values were derived using either analyses of dose-response or selected no-observed-adverse-effect levels or lowest-observed-adverse-effect levels (NOAELs or LOAELs). Although this review focused on exposure through inhalation, general population exposure to formaldehyde can occur via inhalation, ingestion, and dermal contact.

The Toxicological Review is organized into the following sections: Executive Summary, Background (Section 1); Assessment Methods (Section 2); Evidence Synthesis and Integration for Hazard Identification (Section 3); Summary of Hazard Identification Conclusions (Section 4); and Dose-Response Analysis (Section 5). Supplemental Information to the Toxicological Review is provided in a separate document, Supplemental Information to the Toxicological Review of Formaldehyde―Inhalation, containing appendices that support hazard identification and dose-response evaluation. The appendices include a brief description of the chemical properties and uses of formaldehyde; information specifically addressing exposure, toxicokinetics, and genotoxicity; supporting information for health hazard conclusions in the Toxicological Review (e,g., documentation of literature searches and study evaluations; additional analyses); dose-response modeling; a list of previous legislation and assessments by other agencies; and responses to external peer-review and public comments received on this IRIS assessment. Additional documents produced during assessment development are available on the IRIS website (http://www.epa.gov/iris).

In this assessment, potential human health hazards from formaldehyde exposure were identified and evaluated. These include sensory irritation; decreased pulmonary function; immune-mediated conditions, focusing on allergies and asthma; respiratory tract pathology; nervous system effects; reproductive and developmental toxicity; and carcinogenicity. These health outcomes were identified based on NRC recommendations on the 2010 draft IRIS assessment (NRC, 2011) and previous reviews of formaldehyde toxicity and health assessments by other agencies, including the International Agency for Research on Cancer (IARC), Agency for Toxic Substances and Disease Registry (ATSDR), and the National Toxicology Program (NTP) (NTP, 2014; IARC, 2012; ATSDR, 1999, 2010). For each health hazard, the literature regarding specific health effects was synthesized within each of the human, animal, and mechanistic streams of evidence and then integrated across the streams of evidence. The evidence integration includes a narrative summary of the key evidence and a corresponding level of evidence judgment (i.e., evidence demonstrates, evidence indicates [likely], evidence suggests, evidence inadequate, or strong evidence supports no effect) as to whether formaldehyde inhalation exposure may pose a human hazard for specific types of cancer or individual noncancer health effects, given sufficient exposure conditions. The assessment provides evidence integration judgments for each unit of analysis that can be reasonably supported by the available health effect-specific evidence base. A unit of analysis is an outcome or group of related outcomes within a health effect category considered together during evidence synthesis. A given health hazard may have a single judgment or multiple judgments at more granular outcome groupings. The evidence integration for cancer concludes with a descriptor summarizing the weight of evidence for cancer according to EPA’s cancer guidelines (U.S. EPA, 2005a). In this assessment, for both noncancer and cancer effects, those with evidence integration judgments of evidence demonstrates or evidence indicates [likely] (see methods in Section 2.6) are advanced for dose-response analysis in Section 5, including the derivation of toxicity values (see methods in Section 2.7).

The Toxicological Review includes an inhalation reference concentration (RfC) value for lifetime exposure. The inhalation RfC (expressed in units of µg of substance/m^3^ air) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous daily exposure of formaldehyde to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. A carcinogenicity assessment was also performed, including derivation of an inhalation unit risk value (IUR), which is an upper-bound excess lifetime cancer risk estimated to result from continuous exposure to an agent at a concentration of 1 μg/m^3^ in air. In addition, organ/system-specific RfCs (osRfCs) were derived for various noncancer health endpoints, when supported by the available evidence. These may be useful when considering cumulative risk scenarios. Multiple candidate RfCs (cRfCs) were sometimes compared before choosing a representative osRfC for a specific organ or system. An osRfC was typically selected from cRfCs based on use of higher confidence studies, and higher confidence in the cRfC derivation (including point-of-departure [POD] selection). Where relevant, mechanistic understanding regarding the development of specific health effects (e.g., temporal progression, potential thresholds in dose-response), as well as knowledge of susceptibility, was used to inform approaches to derive points of departure (PODs), uncertainty factors, or confidence levels for the quantitative estimates (e.g., osRfCs, RfC, IUR). Where possible, the assessment attempts to describe the level of response observed across different exposure levels within the range of the data, and to discuss transparently the uncertainties and assumptions when deriving toxicity value estimates (e.g., cRfCs, IUR). In addition, as the temporal window of exposure relevant to certain outcomes may vary, the window of exposure expected to be most relevant to each toxicity value is discussed in Section 5, Dose-Response Analysis, when applicable.

A confidence level of high, medium, or low was assigned to each cRfC, osRfC, and the overall RfC based on the reliability of the associated evidence and POD calculation(s). Confidence decisions included considerations of the quality, timing, and variability of the exposure estimates in an epidemiological study or the exposure protocols in an animal study. Moreover, higher confidence was placed in the toxicity value when the POD was identified close to the range of the observed data. Finally, confidence in the coverage and quality of the database of studies that informed the hazard conclusion for that organ/system was assigned. The evidence base for different health outcomes varies in size, coverage of critical endpoints, and quality of the studies; this confidence level reflects database completeness for each of the organ systems.

Overviews of the methods used for the Literature Search and Screening (Section 2.2), Study Evaluation (Section 2.3), Data Extraction (Section 2.4), Evidence Synthesis (Section 2.5), Evidence Integration (Section 2.6), and Dose-Response Modeling (Section 2.7) are presented. The Document Map (Table 2-1) provides information on where to find the results and additional documentation for each of these steps for each health effect included in this Toxicological Review.

Table 2-1 Document map for each health topic and assessment development stage (Sections at the top indicate the location of the methods or relevant results; Appendices at the bottom indicate the location of supporting documentation)

Health effect or mechanisms searches | Evidence identification | Study evaluation | Evidence synthesis and integration | Dose-response analysis
Sensory Irritation | Section 2.2.2; Appendix B.2.2 | Section 2.3.2; Appendix B.3.2 | Section 3.2.1; Appendix C.2 (reflex bradypnea) | Section 5.1; Appendix D.1.1
Pulmonary Function | Section 2.2.3; Appendix B.2.3 | Section 2.3.3; Appendix B.3.3 | Section 3.2.2; Appendix C.5 (acute or short-term studies) | Section 5.1; Appendix D.1.2
Allergies and Asthma | Section 2.2.4; Appendix B.2.4 | Section 2.3.4; Appendix B.3.4 | Section 3.2.3; [see also Appendix C.7] | Section 5.1; Appendix D.1.3
Respiratory Tract Pathology | Section 2.2.5; Appendix B.2.5 | Section 2.3.5; Appendix B.3.5 | Section 3.2.4; Appendix C.6 (short-term animal studies); [see also Appendix C.7] | Section 5.1; Appendix D.1.4
Noncancer Respiratory Mechanistic Evidence | Section 2.2.6; Appendix B.2.6 | Section 2.3.6; Appendix B.3.6 | Sections 3.2.1—3.2.5; Appendix C.7 | N/A
Nervous System Effects | Section 2.2.7; Appendix B.2.7 | Section 2.3.7; Appendix B.3.7 | Section 3.3.1; No appendix materials | N/A
Developmental or Reproductive Effects | Section 2.2.8; Appendix B.2.8 | Section 2.3.8; Appendix B.3.8 | Section 3.3.2; No appendix materials | Section 5.1; Appendix D.1.5
Respiratory Tract Cancers | Section 2.2.9; Appendix B.2.9 | Section 2.3.9; Appendix B.3.9 | Section 3.2.5; No appendix materials | Section 5.2.1; Appendix D.2.1 (human data) and D.2.2 (animal data)
LHP Cancers | Section 2.2.9; Appendix B.2.9 | Section 2.3.9; Appendix B.3.9 | Section 3.3.3; No appendix materials | Section 5.2.2; Appendix D.2.3
Other cancers | Section 2.2.9; Appendix B.2.9 | N/A | Appendix C.8 | N/A
Cancer Mechanistic Evidence | Section 2.2.10; Appendix B.2.10 | Section 2.3.10; Appendix B.3.10 | Sections 3.2.5 and 3.3.3; Appendix C.3 (Genotoxicity) | N/A

Note: evidence on the toxicokinetics of inhaled and endogenous formaldehyde is summarized in Section 3.1 and Appendix C.1 and D.2.4, with discussions related to the implications of these data throughout Sections 3.2, 3.3, and 5.

## 2.2 LITERATURE SEARCH AND SCREENING METHODS

### 2.2.1 Overview of Approach

#### Literature Search Strategy

A separate search strategy was developed for each health hazard considered in the assessment (Table 2-2). Generally, health outcomes and search terms were selected after reviewing the draft Toxicological Review for Formaldehyde (2010) and other relevant health assessments or reviews of formaldehyde toxicity.

The primary literature search strategies involved keyword-based queries of PubMed (https://www.ncbi.nlm.nih.gov/pubmed/) and Web of Science (https://apps.webofknowledge.com/), with many of the health effect-specific searches including additional queries of Toxline (https://toxnet.nlm.nih.gov/newtoxnet/toxline.htm) and/or DART (https://toxnet.nlm.nih.gov/newtoxnet/dart.htm). Initial searches were conducted in 2012 (an exception being the search for mechanisms related to respiratory health effects, which was initially conducted in 2014) and updates were performed annually (i.e., in either September or October) through 2016 in support of development of a 2017 Step 1 draft IRIS formaldehyde-inhalation assessment, which was suspended in 2017 and re-started in 2021 (discussed more below). All search strings were submitted as keyword searches, which in the case of PubMed includes MeSH terms by default, except as specified with tags like [majr] which limited the search to only when the term (and any selected subheadings) are indexed as a major topic heading (not all MeSH terms); as defined by PubMed, a MeSH Major Topic is one of the main topics discussed in an article. The search results were augmented by secondary search approaches, including “forward searching” of key references, review of topic-specific meeting abstracts (e.g., from Society of Toxicology and International Society of Environmental Epidemiology annual meetings), and curation of reference lists in the identified studies, published reviews, meta-analyses, and national or international health assessments of formaldehyde, and Review of abstracts (initial title search for formaldehyde, then abstract review) from 2005−2014 presented at International Society of Environmental Epidemiology annual meetings.

The completed draft 2017 IRIS assessment was suspended by EPA (https://www.epa.gov/sites/default/files/2019-4/documents/iris_program_outlook_apr2019.pdf) However, in 2021, development of the IRIS assessment was unsuspended (https://www.epa.gov/sites/default/files/2021-03/documents/iris_program_outlook_mar2021.pdf). At the time of re-start, a separate systematic evidence map (SEM) was developed to identify the relevant literature published since the suspension of the 2017 draft (i.e., from January 2016 to May 2021, intentionally overlapping with the prior searches). The primary focus of the SEM was to identify studies with the potential to impact hazard or toxicity value conclusions. This SEM applied literature search strategies nearly identical to those used to develop the 2017 draft IRIS assessment. However, while earlier literature updates included a search strategy on exposure to formaldehyde and a search specific to hypersensitivity in animals, these research categories were not updated for this search as exposure is not a review topic for the IRIS assessment and the respiratory mechanisms search encompasses hypersensitivity studies. In addition, the SEM update did not include ToxNet, which was migrated to PubMed in 2019.

Table 2-2 General approach to literature search strategies

Databases^a^ | Health effect searches^b^ | Additional mechanistic searches^d^
PubMed; Web of Science ToxNet (for some effects); TSCATS2 (for some effects) | (formaldehyde, formalin, paraformaldehyde, OR CASN 50-00-0) AND:; - Sensory Irritation^c^; - Pulmonary Function^c^; - Immune-Mediated Conditions, focusing on Allergies and Asthma; - Respiratory Tract Pathology; - Developmental and Reproductive Toxicity; - Nervous System Effects; - Site-specific cancer in Humans; - Upper Respiratory Tract Cancer in Animals; - Lymphohematopoietic Cancer in Animals | (formaldehyde, formalin, paraformaldehyde, OR CASN 50-00-0) AND:; - Toxicokinetics; - Inflammation and Immune-related mechanisms; - Mechanistic Studies of Upper Respiratory Tract Cancer, focusing on Genotoxicity^e^; - Mechanistic Studies of Lymphohematopoietic Cancer, focusing on Genotoxicity^e^

CASN, Chemical Abstracts Service Number; TSCATS, Toxic Substances Control Act Test Submissions.

a PubMed: http://www.ncbi.nlm.nih.gov/pubmed/, Web of Science: http://apps.webofknowledge.com/WOS_GeneralSearch_input.do?product=WOS&search_mode=. ToxNet: toxicology information previously contained in ToxNet were integrated into other NLM products in 2019 (see https://www.nlm.nih.gov/toxnet/index.html for where to access).

b Specific parameters and keywords for each hazard-specific database search strategy are included in Appendix B.2.

c A systematic search strategy was not applied to the database of animal studies on this health outcome. Sensory irritation in animals is a well described phenomenon. For pulmonary function, there was an extensive set of research studies on humans, and therefore, the few studies on this endpoint in animals were not reviewed.

d Separate, systematic literature searches were performed to augment the analyses of mechanisms relevant to health effect-specific searches.

e Search strategy developed for the SEM.

#### Literature Screening

Studies were screened for relevance for a specific health effect based on inclusion and exclusion criteria organized according to PECO (Populations, Exposures, Comparators, and Outcomes) category^3^. References that had potential relevance to more than one health effect were identified and screened within each category. The exposure criteria were of particular importance, and inclusion was limited to studies with direct measurement or reconstruction (e.g., use of a job-exposure matrix applied to indirect formaldehyde measurements) of formaldehyde exposure rather than reliance on proxies such as construction materials or age of a house. PECOs tailored to mechanistic studies were also used. Other exclusions were based on specific criteria relating to each health hazard, which are summarized in each of the respective health hazard sections below.

From 2012–2016, this screening was performed using title and abstract information or hand curation of the full text articles (when screening decisions could not be made based on the abstract) in Endnote libraries. Studies identified in the 2021 SEM database searches were imported into DistillerSR software (https://www.evidencepartners.com/products/distillersr-systematic-review-software/) for screening. Both title/abstract (TIAB) and full-text screening were conducted by two independent reviewers and any screening conflicts were resolved by discussion between the primary screeners with consultation by a third reviewer if needed. For citations with no abstract, articles were initially screened based on title relevance and page numbers (articles two pages in length or less are assumed to be conference reports or editorials). Eligibility status of non-English studies was assessed using the same approach with online translation tools or engagement with a native speaker used to facilitate screening. Access to the example screening form in DistillerSR is available upon request for users who have DistillerSR access. See Sections 2.2.2−2.2.10 for PECO criteria for specific health effects and types of mechanisms.

This assessment focuses on studies of inhalation exposure to formaldehyde in indoor air. Ambient levels of formaldehyde in outdoor air are significantly lower than those measured in the indoor air of workplaces or residences, and the exposure range was narrow in epidemiological studies of ambient exposure (<0.005 mg/m^3^), limiting their sensitivity to find any associations with health outcomes even if they existed. Temporal (seasonal and diurnal) and spatial variation in formaldehyde concentration is strongly influenced by photochemical interactions and traffic emissions (Luecken et al., 2012). Consequently, the potential for exposure misclassification for estimates of individual exposure using mean formaldehyde concentrations from central outside monitors is greater than from indoor formaldehyde measurements. Therefore, the few studies examining health effects in relation to outdoor formaldehyde concentrations were excluded. In addition, although some uncertainties remain, the organization and analyses in the assessment assume that inhaled formaldehyde is not distributed to an appreciable extent beyond the upper respiratory tract to distal tissues; thus, it is assumed that inhaled formaldehyde is not directly interacting with tissues distal to the portal of entry (POE) to elicit systemic effects. Therefore, as a deviation from the literature screening approach applied to develop the 2017 draft, studies of exposure routes not involving inhalation, including in vitro studies involving cells from distal tissues, were not considered to be PECO relevant for the 2021 SEM literature update and were excluded; an exception to this was applied for studies of genotoxicity. Similarly, it is assumed that formaldehyde does not cause appreciable changes in normal metabolic processes associated with formaldehyde in distal tissues. Thus, studies examining potential associations between levels of formaldehyde or its metabolites in tissues distal to the POE (e.g., formate in blood or urine, brain formaldehyde levels) were excluded for most health outcomes, particularly effects on systemic tissues such as the nervous system and reproductive and developmental effects. However, studies of endogenous formaldehyde and mechanisms with potential relevance to circulating hematopoietic precursor cells and lymphohematopoietic cancers were considered.

#### Study Inclusion from the 2021 SEM

For the 2021 SEM literature update, after screening the studies for PECO relevance, only those studies meeting the PECO criteria and judged as possibly impactful (i.e., likely, based on the study design and tested exposure levels, to have a potential impact on the hazard conclusions or toxicity values) are synthesized in this assessment. This process relied on information collected into a literature inventory and expert judgment by two reviewers. The literature inventory (see Appendix B.2) included the following:

- For animal studies, the following information was captured: formaldehyde source, study type (e.g., acute, chronic, developmental), duration of treatment, route, species, strain, sex, exposure levels tested, exposure units, and endpoints assessed.
- For epidemiological studies, the following information was summarized: population type (e.g., residential/school based, occupational, other), study design (e.g., cross-sectional, cohort, case-control, ecological, case-report, controlled trial), study location, lifestage (adults, children/infants), exposure measurement (air sampling, occupational history, other), and endpoints assessed.
- For mechanistic studies, the information gathered was dependent on the study type: human in vivo, animal in vivo, in vitro/ex vivo, or dosimetry/pharmacokinetic modeling. For dosimetry/pharmacokinetic modeling references, a summary from the paper’s abstract was excerpted. For all types of mechanistic studies, study details and exposure metrics were summarized along with the endpoints assessed.

General considerations for designating studies as possibly impactful are included below, with the specific rationales documented in the SEM study summary tables:

- Studies with chronic or subchronic exposure durations or including exposure during reproduction or development, were considered more impactful than studies with acute or shorter-term exposure durations (e.g., <4 weeks in rodent studies).
- Animal studies with multiple dose groups covering a broad range of dose levels, and specifically including lower exposure levels, were considered more impactful than single-dose studies.
- Animal studies employing exposure to formaldehyde without methanol co-exposure (e.g., generated from paraformaldehyde) and with adequate inhalation exposure administration methods were considered more impactful. Methanol, present in aqueous formaldehyde solutions to inhibit polymerization, is a potential confounder of associations between observed health outcomes and formaldehyde exposure via formalin. The test article used to generate the formaldehyde atmosphere and controls in experimental studies was an important consideration, particularly for non-respiratory health effects.
- More apical endpoints and those most directly related to the mechanistic uncertainties identified as most relevant to drawing hazard or dose-response judgments were considered more impactful. The specifics of this consideration vary depending on the health outcome(s) of interest. In some cases, this relevance determination relates to the potential human relevance of the endpoints, while in others this relates to an ability to infer adversity.
- For human studies, prioritization considerations depended on the health effect category, formaldehyde exposure levels, and the extent of the evidence base supporting the hazard conclusions. Studies of noncancer respiratory outcomes identified in the PECOs among residential populations or school-aged children were prioritized over occupational studies, which typically involve higher formaldehyde concentrations. Any study of reproductive or developmental outcomes that conducted an exposure assessment (qualitative or quantitative) for formaldehyde was considered possibly impactful. In addition, with some exceptions documented in the inventory tables, studies of ALS, genotoxicity endpoints, or PECO identified cancer outcomes that conducted an exposure assessment (qualitative or quantitative) for formaldehyde were generally considered possibly impactful.

Studies meeting PECO criteria that were judged to have no impact on assessment conclusions or toxicity values are summarized in Appendix B.2, along with explanations for these decisions. These latter studies are not further discussed or synthesized in the assessment.

#### Documentation

Evidence identification decisions are documented in Appendix B.2 and the formaldehyde page of the U.S. EPA’s Health Effects and Research Online (HERO) database (https://hero.epa.gov/hero/) and they are summarized in Table 2-3 below. The formaldehyde HERO page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/4051) was developed to present a consolidated view of the search and screening decisions for this assessment for the literature identified through 2016 and in the subsequent 2021 SEM. Tags for literature searching (under “literature identification”) indicate from which electronic database each study was identified, noting that some studies were identified in duplicate across databases, or if considered studies were identified through other mechanisms (lists of reference from other or older formaldehyde assessments; lists of references from review articles screened for health effect-specific PECO studies; guidelines or methodological instructions; and other studies not otherwise tagged to a specific electronic database during import). Also tracked, for each health effect-specific series of literature searches including the 2021 SEM, are the screened studies, namely those identified as supplemental (e.g., a review; non-inhalation routes of exposure for some searches), those not meeting the PECO criteria that were excluded, and those identified as meeting the PECO criteria, with the latter bin including an additional tag for being identified as possibly impactful or not in the 2021 SEM. Thus, this HERO page can be used to easily navigate through the higher-level screening decisions for each health effect-specific search.

Table 2-3 Summary of literature search and screening

Health effect and mechanisms searches^a^ | Identified studies^b^ | Excluded studies^b^ | Supplemental studies^b^ | Met PECO^b^ | Met PECO SEM decisions
Health effect and mechanisms searches^a^ | Identified studies^b^ | Excluded studies^b^ | Supplemental studies^b^ | Met PECO^b^ | Possibly impactful^c^ | Not impactful^c^
Noncancer
Sensory Irritation in Human Studies | 979 | 820 | 97 | 62 | 1 | 4
Pulmonary Function in Human Studies | 353 | 262 | 30 | 61 | 1 | 5
Immune-Mediated Conditions in Human Studies, Including Asthma and Allergy | 6,206 | 5,649 | 499 | 58 | 11 | 5
Respiratory Tract Pathology in Human Studies | 1,598 | 1,577 | 7 | 14 | 0 | 1
Respiratory Tract Pathology in Animal Studies | 2,049 | 1,814 | 174 | 61 | 1 | 9
Mechanistic Studies Related to Noncancer Respiratory Effects, Including Immune Changes and Inflammation | 9,894 | 8,729 | 966 | 199 | 8 | 48
Nervous System Effects | 9,435 | 9,252 | 91 | 92 | 2 | 12
Reproductive and Developmental Effects | 11,040 | 10,647 | 326 | 67 | 5 | 4
Cancer
Cancer in Human Studies | 2,552 | 2,419 | 76 | 67 | 3 | 3
Respiratory Tract (Nasal) Cancer in Animal Studies | 945 | 893 | 27 | 25 | 1 | 1
Mechanistic Studies of Respiratory Tract Cancer, Genotoxicity Focus | 744 | 417 | 101 | 225 | 8 | 19
Lymphohematopoietic (LHP) Cancer in Animal Studies | 117 | 81 | 28 | 8 | 1 | 1
Mechanistic Studies of LHP Cancer, Genotoxicity Focus | 3,307 | 3,019 | 150 | 138 | 14 | 11

a These counts reflect the summary decisions documented in the Formaldehyde HERO page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/4051). Note that numbers of studies in each bin in HERO can differ from the numbers of studies elsewhere, including in literature flow diagrams presented in the Appendix (e.g., HERO tracks as separate articles the parent articles and their translations, unpublished reports of published data, supplemental materials to published articles, and erratum).

b Studies identified in 2012–2016 annual searches and the 2021 SEM.

c SEM-related possibly impactful and not impactful judgments for studies meeting PECO in the SEM (see below for health effect-specific details).

### 2.2.2 Sensory Irritation PECO Criteria and Search Summary

The sensory irritation review focused on symptoms of irritation in humans, primarily ocular, nasal, and throat symptoms. Epidemiological and controlled exposure studies describing reports of sensory irritation based on questionnaire responses or objective measures, such as eye blink frequency or conjunctival redness, were included while other epidemiological study designs were excluded. There is an extensive database of research studies on relevant apical endpoints in humans after formaldehyde exposure. Systematic searches for studies of sensory irritation in experimental animals were not conducted. However, mechanistic data informing this health effect were identified and evaluated as part of the overarching review of mechanistic data relevant to potential respiratory health effects (see Appendix B.2.6, B.3.6, and C.7 for details).

PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-4. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.2.

Table 2-4 PECO inclusion and exclusion criteria for studies of sensory irritation in humans

PECO Category | Included | Excluded^a^
Population | - Human | - Animals (note: already well-established; see Appendix C.2)
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air | - Not formaldehyde; - Dermal^b^; - Exposure defined using job title/industry; - Outdoor exposure
Comparison | - Evaluated risk in relation to variation in exposure based on level, duration, or other parameter. | - Case reports; - Surveillance analysis /Illness investigation (no comparison)
Outcome | - Ocular, nasal and throat symptoms | - Exposure studies/no outcome evaluated; - Studies evaluating other health outcomes; - Properties, uses

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

b Dermal irritant effects result from direct dermal, not inhalation, exposure, and thus were excluded.

From the 979 studies identified by the searches, 58 studies identified through 2016 met PECO criteria; 38 were observational epidemiology studies and 20 were controlled exposure studies in human volunteers. Five additional studies from the 2021 SEM met PECO criteria; one study was deemed to be possibly impactful but already had been identified and incorporated by 2017. Thus, zero (0) additional studies from the SEM update were included for the sensory irritation review (see Appendix B.2.2 for details).

Overall, 58 human studies on sensory irritation were evaluated (see Section 2.3.2) for consideration in the Toxicological Review.

### 2.2.3 Pulmonary Function PECO Criteria and Search Summary

The pulmonary function review focused on standard quantitative measures of pulmonary function including spirometric measures, FEV_1_, FVC, and FEF_25_−_75_, as well as PEF measured using a flowmeter. Studies that evaluated both short-term as well as long-term exposure to formaldehyde were included. Observational studies of human populations evaluated exposures in residential communities, school classrooms and university lab courses, and industrial and other workplace settings. Controlled human exposure studies, which exposed subjects for minutes or hours, also were included. Although corresponding quantitative pulmonary function measures can be measured in animals, given the availability of well-conducted human studies and the challenges with conducting (e.g., due to the small size of rodent airways) and interpreting (e.g., the more precise and reliable measures require more invasive techniques) these endpoints (Bates and Irvin, 2003), as well as the sparsity of such studies with formaldehyde (based on prior reviews), systematic searches for studies of pulmonary function in experimental animals were not conducted. The mechanistic evidence informing this health effect was identified and evaluated as part of the overarching review of mechanistic data relevant to potential respiratory health effects (see Appendix B.2.6, B.3.6 and C.7 for details). The PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-5. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.3.

Table 2-5 PECO inclusion and exclusion criteria for studies of pulmonary function in humans

PECO Category | Included | Excluded^a^
Population | - Human | - Animals
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air, or exposure during dissection or embalming | - No formaldehyde specific analyses; - Job title/industry-based analysis; - Dermal; - Outdoor exposure
Comparison | - Evaluated risk in relation to exposure based on level, duration, or other parameter. | - Case reports; - Surveillance analysis /Illness investigation (no comparison)
Outcome | - Reported measure of FVC, FEV, FEF or PEF based on spirometry or flowmeter | - Pulmonary function among asthmatic subjects in controlled human exposure studies (there were evaluated in the section on other respiratory conditions including asthma; - Exposure studies/no outcome evaluated; - Studies of other outcomes

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 353 studies identified by the searches, 53 studies identified through 2016 met PECO criteria; 42 were observational epidemiology studies and 11 were controlled exposure studies in human volunteers. Five additional studies from the 2021 SEM met PECO criteria; one study was deemed to be possibly impactful but already had been identified and incorporated by 2017. Thus, zero (0) additional studies from the SEM update were included for the pulmonary function review (see Appendix B.2.3 for details).

Overall, 53 human studies on pulmonary function were evaluated (see Section 2.3.3) for consideration in the Toxicological Review.

### 2.2.4 Immune-Mediated Conditions (Focusing on Allergies and Asthma) PECO Criteria and Search Summary

The immune-mediated conditions review focused on hypersensitivity (allergy) and on asthma, reflecting the question of whether formaldehyde exposure influences the sensitization response to respiratory allergens; these are well-developed areas of research with respect to immune-related effects of inhalation exposure to formaldehyde. This included the identification of studies of specific health outcomes and particular exposure scenarios in studies of exposed humans (Appendix B.2.4) and relevant mechanistic data identified and evaluated as part of the overarching review of mechanistic data relevant to potential respiratory health effects, the latter of which included studies on hypersensitivity in animals (see Appendix B.2.6, B.3.6 and C.7 for details).

For the human health effect studies, several exposure settings and scenarios were included that encompassed different exposure durations and time windows. These included controlled human exposure studies among asthmatics, residential and school settings, as well as occupational studies. Controlled human exposure studies of pulmonary function change among asthmatic volunteers, including two studies that assessed whether formaldehyde exposure changed the response to an allergen challenge, are summarized in this section, but their results are most informative to the pulmonary function outcome and are included in the integration of evidence in that section (see Section 3.2.2). Specific types of outcome measures within the category of allergic conditions include questionnaire-based ascertainment of history of rhinitis, rhinoconjunctivitis, hay fever, pet allergy, eczema, or dermatitis; physician documentation of a specific diagnosis (e.g., atopic dermatitis); and allergic sensitization based on skin prick tests. Allergic conditions were grouped by site (nose, eyes, skin). Eczema is not a contact allergy but can be triggered by reactions to respiratory and other types of allergens (as well as by other factors). Unlike eczema, which can be triggered by reactions to respiratory and other types of allergens (as well as other factors), food allergies do not result from exposure to respiratory allergens or other inhaled substances. Because this assessment focuses on inhalation exposures only, food allergies are excluded from the literature search strategy. Measures of asthma include questionnaire-based ascertainment of prevalence of current asthma (e.g., within past 12 months), incidence of asthma, and measures of asthma control (based on symptom frequency and medication use in the past 2–4 weeks). EPA considered “ever had asthma” to be of limited use in this review, as the formaldehyde measures available do not reflect cumulative exposures that could be related to cumulative risk, and thus EPA did not include studies limited to “ever had asthma.”

In addition, separate from asthma, EPA also considered studies of wheeze episodes, with or without lower respiratory infection, in infants and young children (≤ 3 years). The studies of wheezing episodes in infants were not classified as studies of asthma per se but could be indicatives of respiratory effects with implications for subsequent risk. These studies were evaluated as a separate health endpoint.

Given the frequency and general transiency of upper respiratory infections such as the common cold in human populations (which may complicate epidemiological evaluations), as well as their generally benign nature, this endpoint is not discussed in detail in this assessment, although several studies on this topic were identified and evaluated in the wider context of potential mechanisms for respiratory health hazards (see Appendix B.2.6, B.3.6 and C.7).

One potential mechanism for inducing hypersensitivity is the potential to elicit a formaldehyde-specific antibody response, specifically IgE. The presence of formaldehyde-specific IgE in workers occupationally exposed to formaldehyde was described in case reports (Vandenplas et al., 2004; Kim et al., 2001), but larger studies in exposed populations or in asthma patients indicate this is a relatively uncommon occurrence, seen in no or only a few individuals (Wantke et al., 1996b; Thrasher et al., 1990; Krakowiak et al., 1998; Hisamitsu et al., 2011; Grammer et al., 1990; Doi et al., 2003). Formaldehyde-specific IgE was not included as an outcome for analysis in this section. However, a broader consideration of antibody responses following formaldehyde exposure is considered in the mechanistic evaluation of potential respiratory effects (see Appendix B.2.6, B.3.6 and C.7).

Based on the ultimate conclusion that the toxicity studies in animals were most appropriately reviewed as mechanistic information (see explanation in Section 3.2.3 of the Toxicological Review), the experimental studies identified as a result of this literature search are evaluated and described as mechanistic studies related to noncancer respiratory health effects (see Appendix B.2.6, B.3.6 and C.7). As noted previously, this search for animal hypersensitivity studies was not conducted for the 2021 SEM. In regard to the experimental studies identified by this literature search, particular emphasis was placed on the identification of studies examining the following endpoints:

- Airway inflammatory responses to sensitizing antigens, such as bronchoconstriction and airway hyperresponsiveness. (Studies describing the development of immunological or allergy animal models were not included, however.)
- Biomarkers relating to potential mechanisms in animal toxicology studies, such as eosinophil infiltration, immunoglobulins (e.g., total, or anti-allergen specific IgE or IgG), and cytokines pertinent to hypersensitivity responses, and neurogenic mechanisms of airway inflammation.

PECO category inclusion and exclusion criteria for selection of studies are summarized in Table 2-6 and Table 2-7, respectively, for human and experimental animal studies. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.4.

Table 2-6 PECO inclusion and exclusion criteria for studies of allergy and asthma studies in humans

PECO Category | Included | Excluded^a^
Population | - Human | - Animals
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air | - Not formaldehyde; - Outdoor formaldehyde exposure; - Dental-related exposures or cosmetic and other dermal-related exposures; - Exposure via dialysis; - Formaldehyde as fixative
Comparison | - Evaluate risk in relation to exposure based on level, duration, or other parameter. | - Case reports (selected references used for illustration); - Limited exposure range
Outcome | - Allergy symptoms^b^; - Skin prick tests; - Incidence of specific allergies; - Prevalence of current asthma^a^; - Incidence of asthma; - Asthma control or severity; - Wheezing symptoms and other lower respiratory tract conditions in infants and children < 5 years.; - Controlled exposure pulmonary function studies in people with asthma | - Sick building syndrome, sick building symptoms, chemical sensitivity studies; - Contact dermatitis, eczema, or urticaria in studies of worker populations with likely dermal exposure^c^; - Formaldehyde-specific antibodies (FA-Ig); - Pulmonary function in controlled exposure studies in people without asthma [these studies are included in Section A.5.3. Pulmonary Function]; - Lifetime prevalence of asthma (“Ever had asthma” or “ever had wheezing episode”)

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

b Based on the methods used in the American Thoracic Society questionnaire (Ferris, 1978) or subsequent instruments that built upon this work, such as the International Study of Arthritis and Allergies in Children (ISAAC) and European Community Respiratory Health Survey (ECHRS) questionnaires.

c Contact dermatitis is a well-established effect from dermal exposure and the effects of dermal exposure are not a focus of this review; thus, studies of contact dermatitis from dermal exposures are excluded.

Table 2-7 PECO inclusion and exclusion criteria for studies of hypersensitivity in experimental animals

PECO Category | Included | Excluded^a^
Population | - Mammals (rodents, rabbits, nonhuman primates, pigs, dogs, and sheep have been used in hypersensitivity studies) | - Humans; - Non-mammalian Species
Exposure | - Inhalation route, formaldehyde | - Not formaldehyde; - Oral or dermal exposure protocol; - In vitro exposure
Comparison | - One or more exposure group compared to control | - No control group
Outcome | - Bronchoconstriction or airway hyperresponsiveness measures; - Total or anti-allergen-specific IgE or IgG; - Eosinophil infiltration in lung; - Th2 cytokines (e.g., IL-4, IL-5) | - General chronic bioassay measures (e.g., organ weight, tumor incidence); - Host resistance assays.; - Antibody responses not involving respiratory sensitizers (e.g., sheep red blood cells, tetanus toxoid); - Dermal sensitization measures; - In vitro studies, measures of inflammation and irritation (e.g., TNF-a, ROS), and formaldehyde-specific antibody studies were identified using a more specific search string in Section A.5.6.

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 6,204 studies identified by the searches, 36 studies identified through 2016 met PECO criteria; 27 were observational epidemiology studies and 9 were controlled exposure studies in human volunteers. Sixteen additional studies from the 2021 SEM met PECO criteria; 11 studies were deemed to be possibly impactful and thus were included in the allergy and asthma review (see Appendix B.2.4 for details).

Overall, 47 human studies were evaluated (see Section 2.3.4) for consideration in the Toxicological Review.

An additional 16 mechanistic studies in exposed animals were identified and considered as part of the literature on mechanisms related to noncancer respiratory effects; see Section 2.2.6).

### 2.2.5 Respiratory Tract Pathology PECO Criteria and Search Summary

The respiratory tract pathology review focused on histopathological endpoints and signs of pathology in nasal and respiratory tissues. Reports from observational epidemiology studies of effects in more distal respiratory tissues in humans are not common in the literature since measurements of those endpoints are highly invasive; thus, these endpoints were not a focus of the human evidence synthesis.^4^ Similarly, although included in the search strings to ensure capture of all potentially relevant studies, signs such as changes in mucous flow rate and rhinitis were tracked as supplemental and included in the discussion of mechanisms of respiratory inflammation and immune system-related responses rather than as an outcome included in the human or animal respiratory tract pathology evidence syntheses.

Systematic literature searches were conducted separately to identify health effect studies in humans and in experimental animals. The focus of the searches was on primary studies involving subchronic or chronic exposure durations using measurements of formaldehyde in workplace air and histopathological endpoints in nasal tissue in humans and measures of respiratory pathology in animal species, primarily rodents and nonhuman primates. The mechanistic evidence informing this health effect was identified and evaluated as part of the overarching review of mechanistic data relevant to potential respiratory health effects (see Appendix B.2.6, B.3.6, and C.7 for details). PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-8 for humans, and 2-9 for animals. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.5.

Table 2-8 PECO inclusion and exclusion criteria for studies of respiratory pathology in humans

PECO Category | Included | Excluded^a^
Population | - Humans | - Animals
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air | - Not about formaldehyde; - Not inhalation (e.g., dermal exposure)
Comparison | - Evaluated risk in relation to variation in exposure based on level, duration, or other parameter | - Case reports; - Surveillance analysis/Illness investigation (no comparison)
Outcome | - Histopathology and signs of pathology in nasal tissues | - Other health endpoints; - Nasal symptoms (e.g., rhinitis; mucous flow rate); studies of these outcomes were considered as part of the immune-mediated conditions or MOA analyses (see Sections 2.2.4 and 2.2.6, respectively); - Not a health study; - Exposure studies/no outcomes evaluated

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

Table 2-9 PECO inclusion and exclusion criteria for studies of respiratory pathology in animals

PECO Category | Included | Excluded^a^
Population | - Experimental animals (rodents, nonhuman primates, etc.) | - Humans; - nonmammalian species (note: nonmammalian species tagged to the respiratory mechanistic search for this effect)
Exposure | - Inhalation exposure, formaldehyde or test article generating formaldehyde | - Not formaldehyde (or formaldehyde exposure not quantified); - Dermal or oral exposure or other noninhalation exposure; - Endogenous properties
Comparison | - One or more exposure group compared to control | - No control group
Outcome | - Respiratory tract pathology; - MOA for pathology (note: these are evaluated and discussed in the overarching MOA section; see Appendix B.2.6, B.3.6 and C.7) | - Assessment of formaldehyde exposure; - Chemical properties; - Formaldehyde use in methodology or treatment; - Not related to respiratory tract pathology

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 1,598 human studies and 2,049 animal studies identified by the searches, 12 human (observational epidemiology) and 41 animal studies identified through 2016 met PECO criteria. One additional human and 10 animal studies from the 2021 SEM met PECO criteria but was not considered to be potentially impactful; one of the animal studies was deemed to be possibly impactful but had already been identified and incorporated by 2017. Thus zero (0) additional studies form the SEM update were included for the respiratory pathology review (see Appendix B.2.5 for details).

Overall, 53 studies (12 human studies, 41 animal studies) were evaluated (see Section 2.3.5) for consideration in the Toxicological Review.

An additional 35 studies potentially related to the MOA for respiratory tract pathology and other respiratory effects, including studies of cell proliferation and mucociliary function, were considered as part of the literature on mechanisms related to noncancer respiratory effects (see Section 2.2.6).

### 2.2.6 PECO Criteria and Search Summary for Mechanistic Information Related to Noncancer Respiratory Effects, including Inflammation and Immune Changes

This review of mechanistic information related to noncancer respiratory system effects included a specific focus on studies relevant to potential inflammation- and immune-related changes. This effort was undertaken to identify mechanistic information related to changes in the respiratory tract, blood, and lymphoid tissues that might not have been captured by health effect-specific systematic searches, including studies of cell proliferation and mucociliary function (note: this gap-filling search strategy was initiated in 2014). Given the breadth of this topic, this section uses a hierarchical approach to screen, sort, and distill information from over 10,000 references identified across multiple searches. Thus, additional steps were taken to focus this analysis on the most influential information. In addition to criteria identifying studies as relevant to assessing potential respiratory system changes, studies that failed to report a specific estimate of formaldehyde exposure (e.g., concentration, duration) were not considered. Nonmammalian models and tissue systems other than those that might be related to formaldehyde-induced respiratory effects (i.e., other than studies of the respiratory tract, or circulatory or immune-related effects) were excluded. Also, studies of in vitro exposure to formaldehyde in solution and of exposure routes other than inhalation, which may inform mechanistic understanding, were initially kept for possible further review or qualitative support of POE-related findings. However, given the large number of studies reporting results from inhalation exposure in vivo or gaseous exposure of airway cells, and considering the uncertainties associated with the toxicokinetics of noninhalation exposures, these comparably far less influential mechanistic data were ultimately not included in the final analysis described herein. PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-10. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.6.

Table 2-10 PECO inclusion and exclusion criteria for mechanistic information relevant to noncancer respiratory effects, including inflammation and immune changes

PECO Category | Included | Excluded^a^
Population | - Experimental animals; - Humans | - Irrelevant species or matrix, including nonanimal species (e.g., bacteria) and studies of inorganic products
Exposure | - Quantified (e.g., levels; duration) exposure to formaldehyde in indoor air | - Not specific to formaldehyde (e.g., other chemicals); - No specific comparison to formaldehyde exposure alone (e.g., formaldehyde levels, duration, or similar in a study of exposure to a mixture)—NOTE: full text screening only; - Nonrelevant exposure paradigm (e.g., use as a pain inducer in nociception studies); - Outdoor air exposure
Comparison | - Inclusion of a comparison group (e.g., pre- or postexposure; no exposure; lower formaldehyde exposure level) | - Case reports (selected references used for illustration)
Outcome | - Examining mechanistic endpoints relevant to interpretations of potential respiratory health effects | - Not relevant endpoints for section, including carcinogenicity studies and endpoints related to contact dermatitis; - Exposure or dosimetry studies; - Use of formaldehyde in methods (e.g., for fixation); - Processes related to endogenous formaldehyde; - Related to hazard endpoints only (including genotoxicity; see those hazard sections)—NOTE: full text screening only

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 9,824 studies identified by the searches, 140 studies identified through 2016 met PECO criteria; 56 additional studies from the 2021 SEM met PECO criteria. Of these newer studies, 8 were deemed to be possibly impactful and thus were included in the inflammation and immune-mediated mechanisms review (see Appendix B.2.6 for details).

Overall, 148 studies related to potential mechanisms informing noncancer respiratory effects were evaluated (see Section 2.3.6) for consideration in the Toxicological Review.

### 2.2.7 Nervous System Effects PECO Criteria and Search Summary for Nervous System Effects

The review of potential nervous system effects focused on inhalation exposure studies in humans or animals that examined objective, apical effects on the nervous system, including structural, behavioral, chemical, and electrophysiological changes, as well as mechanistic studies informing potential biological associations between formaldehyde exposure and nervous system effects. Human (observational epidemiology or controlled exposure) studies of neurobehavioral tests or specific neurological diseases were included.

Studies of symptoms that may be associated with nervous system effects (e.g., headache, fatigue) were excluded. These endpoints are highly subjective as compared to the other available data as these measures were primarily based on self-administered questionnaires that varied in type and specificity and were often conducted due to complaints about symptoms attributed to chemicals in the air. In addition, the symptoms were not rated by severity, were typically grouped with non-nervous system-specific complaints (e.g., related to irritation, such as dry eyes) and at best can only be indirectly related to specific nervous system perturbations. Thus, more objective, and direct nervous system measures were prioritized for review.

In vivo inhalation animal exposure studies were included, but in vitro studies and studies of other exposure routes (e.g., oral, injection), including a multitude of studies using formaldehyde exposure (typically hind paw or forepaw injections) as a model to study nociceptive (pain) behaviors in rodents, were not included. These experiments are considered unlikely to reproduce or reflect (for in vitro studies) the distribution of formaldehyde and its metabolites following inhalation exposures (see Section 3.1) and most are confounded by methanol in the aqueous formaldehyde formulations, reducing the ability of these experiments to attribute any observed effects to formaldehyde. Unlike formaldehyde, methanol, a known neurotoxicant, is transported in the blood to nervous system tissues. In addition, studies examining nervous system effects (e.g., memory loss; neurodegeneration) associated with increases in endogenous formaldehyde levels in the brain were identified by the literature search but excluded because formaldehyde inhalation does not appear to cause appreciable changes in formaldehyde levels in nonrespiratory tissues and no hypothesis currently exists to explain how inhaled formaldehyde would affect endogenous formaldehyde levels in the CNS^5^.

PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-11 for humans, and Table 2-12 for animals. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.7.

Table 2-11 PECO inclusion and exclusion criteria for studies of nervous system effects in humans

PECO Category | Included | Excluded^a^
Population | - Humans | - Animals
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air, or exposure during dissection or embalming | - No formaldehyde specific analyses; - Job title/industry-based analysis; - Dermal; - Outdoor exposure
Comparison | - Evaluated risk in relation to exposure based on level, duration, or other parameter | - Case reports; - Surveillance analysis /Illness investigation (no comparison)
Outcome | - Objective measures of nervous system effects, including behavior; - Nervous system disease | - Subjective symptoms, including headache, fatigue, etc.

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

Table 2-12 PECO inclusion and exclusion criteria for studies of nervous system effects in animals

PECO Category | Included | Excluded^a^
Population | - Experimental animals | - Nonmammalian and nonanimal species (e.g., bacteria), and studies of inorganic products
Exposure | - Quantified (e.g., levels; duration) exposure to inhaled formaldehyde in indoor air | - Not specific to formaldehyde (e.g., other chemicals); - Nonrelevant exposure paradigm (e.g., use as a pain inducer in nociception studies); - In vitro or non-inhalation studies (note: these studies were initially screened as included prior to 2017 but were ultimately concluded not to inform hazard or dose-response decisions for this outcome based on toxicokinetic understanding and were later excluded)
Comparison | - One or more exposure group compared to control | - No control group; - Comparisons to (endogenous) formaldehyde measures in CNS tissues
Outcome | - Nervous system effects that could indicate a hazard (e.g., behavioral, chemical, structural, or physiological); - Mechanistic studies examining aspects of nervous system function | - Subjective symptoms, including headache, fatigue, etc.; - Effects other than noncancer nervous system effects; - Exposure or dosimetry studies; - Use of formaldehyde in methods* (e.g., for fixation); - Processes related to endogenous formaldehyde

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 9,435 studies identified by the searches, 147 studies identified through 2016 met PECO criteria. Based on the toxicokinetics conclusions, the 47 in vitro and non-inhalation exposure studies on this health outcome were ultimately excluded from consideration, leaving 100 included studies; 40 were observational studies in humans, 42 were animal health effects studies and 18 were animal inhalation studies specifically informing potential mechanisms. Fourteen additional studies from the 2021 SEM met PECO criteria; of these 14 studies, two human studies were deemed to be possibly impactful, but one had already been identified and incorporated by 2017. Thus, one additional study from the SEM update was included for the nervous system effects review (see Appendix B.2.7 for details).

Overall, 101 studies (41 human studies, 42 experimental animal studies, and 18 mechanistic studies) were evaluated (see Section 2.3.7) for consideration in the Toxicological Review.

### 2.2.8 Developmental and Reproductive Toxicity PECO Criteria and Search Summary

The developmental and reproductive toxicity review of the available human evidence focused on studies of inhalation exposure and time-to-pregnancy (TTP) as a measure of fecundability,^6^ reproductive parameters in males (e.g., semen parameters), spontaneous abortion, and birth outcomes (e.g., birthweight, malformations). Outcomes assessed in animal toxicology studies included developmental toxicity (prenatal survival, fetal and postnatal growth, and structural alterations and malformations), male reproductive toxicity (sperm count and morphology, testes and epididymal weight and histopathology, and functional measures), and female reproductive toxicity (hormone levels, ovarian and uterine weight and histopathology, and early embryo loss). Functional developmental outcomes (i.e., developmental neurotoxicity) were addressed in the sections on potential nervous system effects. The considerations related to non-inhalation exposure paradigms (including in vitro exposure) and measurements of (endogenous) formaldehyde in systemic tissues relevant to reproduction and development were the same as those applied for potential nervous system effects (see Section 2.2.7).

PECO category inclusion and exclusion criteria used in the screening step are described in Table 2-13 and Table 2-14, respectively, for human and animal studies. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.8.

Table 2-13 PECO inclusion and exclusion criteria for studies of reproductive and developmental effects in humans

PECO Category | Included | Excluded^a^
Population | - Humans | - Animals
Exposure | - Indoor exposure via inhalation to formaldehyde; - Measurements of formaldehyde concentration in air; - Formaldehyde-specific assessments in studies with exposure defined by occupation (wood workers, nurses, pathologists, cosmetologists) | - Not formaldehyde; - Outdoor formaldehyde exposure; - Mixtures or industry/job title analyses; - Not inhalation
Comparison | - Evaluated risk in relation to variation in exposure based on level, duration, or other parameter | - Case reports
Outcome | - Reproductive toxicity (sperm measures); - Time-to-pregnancy (fecundity); - Spontaneous abortion; - Birth outcomes | - Exposure studies/no outcomes evaluated; - Other health outcomes not related to reproduction or development

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

Table 2-14 PECO inclusion and exclusion criteria for studies of reproductive and developmental effects in animals

PECO Category | Included | Excluded^a^
Population | - Experimental animals; - Nonmammalian test species or test paradigms that are relevant for evaluation of developmental or reproductive hazard | - Humans; - Irrelevant species (i.e., non-mammalian species, although established models of reproduction and development, such as chick embryo assays, tagged as potentially relevant supplemental information) or test paradigms
Exposure | - Inhalation route, formaldehyde | - Not formaldehyde; - Noninhalation routes of exposure; - Mixture studies; - Ecological studies
Comparison | - Inclusion of a comparison group (e.g., pre- or postexposure, no exposure, vehicle exposure, lower formaldehyde exposure level) | - No comparison group; - Comparison to (endogenous) formaldehyde measures in systemic tissues relevant to reproduction (e.g., testes)
Outcome | - Pre- and postnatal offspring biomarkers of:; ○ Survival (e.g., resorptions, death); ○ Growth (e.g., body weight); ○ Structural anomalies (e.g., external, skeletal, or soft tissue malformations or variations); ○ Functional deficits; - Adult biomarkers of reproductive toxicity, including:; ○ Gonadotropic hormone measures; ○ Reproductive organ weight; ○ Reproductive organ macro- and microscopic pathology; ○ Sperm measures (count, motility, morphology); ○ Reproductive function (e.g., mating, fertility, parturition, gestation, lactation); ○ Mechanistic data relevant to developmental or reproductive outcomes | - No health outcomes evaluated; - Health outcomes not related to developmental or reproductive toxicity; - Mechanistic data irrelevant to developmental or reproductive outcomes

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 11,037 studies identified by the searches, 55 studies identified through 2016 met PECO criteria; 20 were observational studies in humans, and 35 were animal inhalation studies. Nine additional studies from the 2021 SEM met PECO criteria; four human and one animal study were deemed to be possibly impactful. One of these human studies already had been identified and incorporated by 2017 and thus only four additional studies (three in humans and one in animals) from the SEM update were included for the developmental and reproductive toxicity review (see Appendix B.2.8 for details).

Overall, 59 studies (23 human studies and 36 experimental animal studies) were evaluated (see Section 2.3.8) for consideration in the Toxicological Review.

### 2.2.9 Carcinogenicity PECO Criteria and Search Summary

Systematic identification and evaluation of the literature database on studies examining the potential for carcinogenicity following formaldehyde exposure was performed separately for the following: (1) human studies of respiratory tract, lymphohematopoietic, or other cancers (including brain, lung, pancreatic, etc.); (2) experimental animal studies of respiratory tract (e.g., nasal) cancers; and (3) experimental animal studies of LHP cancers. Separate descriptions for the human and animal searches are provided below. PECO category inclusion and exclusion criteria used in the screening step for human studies, animal studies of respiratory tract cancer, and animal studies of LHP cancer are described in Tables 2-15, 2-16, and 2-17, respectively. The bibliographic databases, search terms, and specific strategies used to search them, as well as literature flow diagrams and other screening documentation, are provided in Appendix B.2.9.

#### Cancer Studies in Humans

Multiple review articles and meta-analyses have examined the epidemiologic evidence informing potential associations between formaldehyde and cancer endpoints (Zhang et al., 2009; Ojajärvi et al., 2000; Collins et al., 1997; Collins et al., 2001; Collins and Lineker, 2004; Bosetti et al., 2008; Blair et al., 1990; Bachand et al., 2010). The vast majority of studies focused on cancers of the upper respiratory tract (URT) and LHP system. Other cancer endpoints reported in the literature include cancers of the bladder, brain, colon, lung, pancreas, prostate, and skin. However, aside from cancer of the brain and lung, few studies showed any evidence of increased risks. Given the large number of studies available on URT and LHP cancers, the other endpoints were not included in the hazard evaluation. As numerous studies reported data on cancers of the brain or lung, a summary of the available studies for each of these endpoints is provided in Appendix C.8.1 for information; however, a limited review of the available studies did not suggest any consistent association with formaldehyde exposure and, as such, these endpoints were also not formally reviewed.

For the hazard evaluation, the URT cancer endpoints were restricted to specific cancers (i.e., nasopharyngeal cancer, sinonasal cancer, cancers of the oro- and hypopharynx, and laryngeal cancer). The occurrences of URT cancers in humans have been described and grouped according to the International Classification of Disease (ICD) coding rubrics. Rarely, cancers of the buccal cavity as a whole are reported, but as this grouping includes lip, tongue, salivary glands, gums, and the floor of the mouth, which combine cancers of potentially different etiology and cell origin, the collection of cancers of the buccal cavity are not reviewed here. The specific LHP cancers that were formally reviewed were Hodgkin lymphoma, multiple myeloma, myeloid leukemia, lymphatic leukemia. Non-Hodgkin lymphoma is a nonspecific grouping of dozens of different lymphomas and classification systems for specific subtypes have changed over time, complicating the synthesis of study results for this cancer type. If formaldehyde is associated with particular non-Hodgkin lymphoma subtypes, then these studies might be not sensitive enough to detect an association. As review articles and an initial review of the available literature did not suggest an association between formaldehyde exposure and non-Hodgkin lymphoma, this endpoint was not formally reviewed.

Table 2-15 PECO inclusion and exclusion criteria for evaluation of studies of cancer in humans

PECO Category | Included | Excluded^a^
Population | - Human | - Animals
Exposure | - Exposure assessment for formaldehyde; - Industries or occupations known to involve exposure to formaldehyde | - Not formaldehyde; - Outdoor formaldehyde exposure
Comparison | - Evaluated risk in relation to variation in exposure based on level, duration, or other parameters | - Case reports
Outcome | - Nasopharyngeal cancer; - Sinonasal cancer; - Cancers of the oro- and hypopharynx; - Laryngeal; - Specific lymphohematopoietic cancers (i.e., Hodgkin lymphoma, multiple myeloma, myeloid leukemia, lymphatic leukemia | - Bladder, colon, pancreas, prostate, and skin; - Brain and lung cancer studies were initially included but were subsequently excluded from the systematic review (tracked as supplemental); - “Buccal cavity”; - Non-Hodgkin lymphoma

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents, secondary analyses), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker). Note that some cancer studies were initially categorized as meeting PECO before it was understood that some of those represented additional follow-ups of cohort studies of secondary analyses.

b For cohort studies with more than one follow-up paper, earlier studies without unique data are tracked as ‘Met PECO’, but only the most recent follow up was included in the evidence syntheses.

From the 2,551 human cancer studies identified by the searches, 63 studies identified through 2016 met PECO criteria. Six additional studies from the 2021 SEM met PECO criteria; three were deemed to be possibly impactful. One of these human studies already had been identified and incorporated by 2017 and the other two studies were reanalysis of studies in the assessment prior to 2017; the two new reanalyses were included in the review of human cancer studies (see Appendix B.2.9 for details).

Overall, 67 human studies were evaluated (see Section 2.3.9) for consideration in the Toxicological Review.

#### Cancer Studies in Animals

Similar to the evidence in humans described above, the animal evidence for cancers other than those of the respiratory tract and the LHP system were not systematically identified or reviewed; rather, any such observations (e.g., if identified through other, health effect-specific searches) are summarily described but not considered in hazard identification or dose-response analyses. The considerations related to non-inhalation exposure paradigms (including in vitro exposure) and measurements of (endogenous) formaldehyde in systemic tissues relevant to LHP cancers were the same as those applied for potential nervous system effects (see Section 2.2.7) and reproductive or developmental effects (see Section 2.2.8). The cancer evidence included from animal experiments included both precancerous lesions (i.e., dysplasia) and neoplasms (tumors).

Table 2-16 PECO inclusion and exclusion criteria for studies of respiratory tract cancers in animals

| Included | Excluded
Population | - Experimental mammals | - Nonmammalian species and other test paradigms
Exposure | - Exposure to formaldehyde for an exposure duration longer than short term | - Not related to formaldehyde (e.g., other chemicals); - Mixture studies; - Short study duration
Comparison | - Inclusion of a comparison group (e.g., pre- or postexposure, no exposure, vehicle exposure, lower formaldehyde exposure level) | - No comparison group
Outcome | - Endpoint evaluation included nasal cancers or other respiratory tract cancers, and dysplasia | - Exposure or dosimetry studies; - Related to formaldehyde use in methodology; - Endpoint not respiratory tract cancer

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

Table 2-17 PECO inclusion and exclusion criteria for studies of LHP cancers in animals

PECO Category | Included | Excluded
Population | - Experimental mammals | - Irrelevant species or matrix, including nonanimal and nonmammalian species
Exposure | - Exposure to formaldehyde | - Not related to formaldehyde (e.g., other chemicals)
Comparison | - Inclusion of a comparison group (e.g., pre- or postexposure, no exposure, vehicle exposure, lower formaldehyde exposure level) | - No comparison group; - Comparison to (endogenous) formaldehyde measures in systemic tissues relevant to LHP cancers (e.g., bone marrow)
Outcome | - Endpoint evaluation included LHP cancers and dysplasia | - Exposure or dosimetry studies; - Related to formaldehyde use in methodology; - Endpoint unrelated to LHP cancer

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 945 animal studies identified by the searches on respiratory cancers and the 117 studies identified by the searches on LHP cancers, 19 studies on respiratory (including nasal) cancers and 4 LHP cancer studies identified through 2016 met PECO criteria. Two additional analyses for nasal and two for LHP cancers identified from the 2021 SEM met PECO criteria. Of these newer analyses meeting the PECO criteria, one study was deemed to be possibly impactful for both cancer types; however, this study already had been identified and incorporated by 2017 and thus zero (0) newer animal studies were considered in the review of animal cancer studies (see Appendix B.2.9 for details).

Overall, 23 animal studies (19 on respiratory tract cancers and 4 on LHP cancers) were evaluated (see Section 2.3.9) for consideration in the Toxicological Review.

### 2.2.10 PECO Criteria and Search Summary for Mechanistic Information Related to Cancer, Focusing on Genotoxicity

Consolidated systematic approaches to identifying the literature examining mechanistic effects relevant to interpreting the potential for formaldehyde to cause either upper respiratory tract (URT) or lymphohematopoietic (LHP) cancers were not performed. Rather, these sections consider studies identified through other health effect-specific literature searches in the context of the specific cancer etiology being evaluated. Supplemental literature relevant to interpreting the biological relevance of some mechanistic data was also identified from review articles and other national-level health assessments. Thus, these sections rely heavily on searches and evaluations performed in the following sections: genotoxicity^7^, respiratory tract pathology, and mechanistic information related to noncancer respiratory effects, including inflammation and immune changes. For the 2021 SEM, supplementing the other health effect- and mechanisms-specific searches, broad and straightforward PECO criteria were used to ensure capture of newer literature (e.g., published after the available national-level health assessments) during screening in Distiller SR for mechanistic information on respiratory tract cancers (Table 2-18) and LHP cancers (Table 2-19). The PECO criteria were based on an assumption of potential direct cellular and molecular interactions with formaldehyde for respiratory cancers but not for LHP cancers.

Table 2-18 PECO inclusion and exclusion criteria for mechanistic studies relevant to respiratory tract cancers, focusing on genotoxicity

PECO Category | Included | Excluded
Population | - Human: Any population and lifestage (occupational or general population, including children and other sensitive populations).; - Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).; - Other: Ex vivo and in vitro studies of genotoxicity or other mechanistic endpoints (including direct interaction with formaldehyde in respiratory and non-respiratory cells) | - Irrelevant species or matrix, including nonanimal species (e.g. bacteria) unless an established model of genotoxicity (e.g., Ames test)
Exposure | - Human: Indoor exposure via inhalation to formaldehyde and including measurements of formaldehyde concentration in air or with quantified exposure defined by occupation (wood workers, nurses, pathologists, cosmetologists); - Animal or Other Experimental: Quantified formaldehyde exposure levels (by any route or in vitro) | - Not formaldehyde; - Human: Outdoor or non-inhalation formaldehyde exposure, or industry/job title analyses; - Animal or Other: Non-experimental dosing regimen or Nonrelevant exposure paradigm (e.g., forepaw injection)
Comparison | - Human: A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits) of formaldehyde, or exposure to formaldehyde for shorter periods of time.; - Animal or Other Experimental: A concurrent control group exposed to vehicle only treatment and/or untreated control (control could be a baseline measurement). | - Human case reports; - No specific comparison to formaldehyde exposure (e.g. formaldehyde levels, duration); - No comparison to controls in animal or other experimental studies; - Mixtures-only comparisons
Outcome | - Mechanistic information relevant to respiratory cancers, including genotoxicity endpoints | - Exposure studies/no outcomes evaluated; - Studies of cancer or tumor incidence or mortality only, including carcinogenicity studies

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

Table 2-19 PECO inclusion and exclusion criteria for mechanistic studies relevant to LHP cancers, focusing on genotoxicity

PECO Category | Included | Excluded
Population | - Human: Any population and lifestage (occupational or general population, including children and other sensitive populations).; - Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages). | - Irrelevant species or matrix, including nonanimal species (e.g. bacteria) unless an established model of genotoxicity (e.g., Ames test); - Ex vivo and in vitro studies that model direct molecular or cellular interaction with inhaled formaldehyde
Exposure | - Human: Indoor exposure via inhalation to formaldehyde and including measurements of formaldehyde concentration in air or with quantified exposure defined by occupation (wood workers, nurses, pathologists, cosmetologists); - Animal or Other Experimental: Quantified formaldehyde exposure levels (by inhalation exposure) | - Not formaldehyde; - Human: Outdoor or non-inhalation formaldehyde exposure, or industry/job title analyses; - Animal or Other: Non-experimental dosing regimen or Nonrelevant exposure paradigm (e.g., forepaw injection); non-inhalation exposure tracked as supplemental
Comparison | - Human: A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits) of formaldehyde, or exposure to formaldehyde for shorter periods of time.; - Animal or Other Experimental: A concurrent control group exposed to vehicle only treatment and/or untreated control (control could be a baseline measurement). | - Human case reports; - No specific comparison to formaldehyde exposure (e.g. formaldehyde levels, duration); - No comparison to controls in animal or other experimental studies; - Mixtures-only comparisons
Outcome | - Mechanistic information relevant to LHP cancers, including genotoxicity endpoints | - Exposure studies/no outcomes evaluated; - Studies of cancer or tumor incidence or mortality only, including carcinogenicity studies

a Additional reasons for not meeting PECO (includes supplemental): Not primary research (e.g., reviews, reports, commentaries, policy documents), meeting abstract, no abstract, methodology paper, nonessential article in a foreign language (e.g., after review of title and abstract, if available, or consultation with native speaker).

From the 744 studies identified through searches on mechanisms relevant to respiratory tract cancer focusing on genotoxicity, 225 studies with relevant primary data (including 8 studies identified as possibly impactful from the 2021 SEM) were considered in the Toxicological Review, with an additional 101 studies tagged as supplemental information (e.g., not primary research articles; primary research articles with little direct relevance to these cancers, such as non-inhalation or in vitro studies of non-respiratory tissues).

From the 3,307 studies identified through searches on mechanisms relevant to LHP cancers focusing on genotoxicity, 138 studies with relevant primary data (including 14 studies that were identified as possibly impactful from the 2021 SEM) were considered in the Toxicological Review, with an additional 150 studies tagged as supplemental information (e.g., not primary research articles; primary research articles with little direct relevance to these cancers, such as non-inhalation or in vitro studies of non-respiratory tissues).

The general approach to evaluating the mechanistic evidence is described in Section 2.3.10.

## 2.3 STUDY EVALUATION METHODS

### 2.3.1 Overview of Approach and Evaluation Criteria

All human and experimental animal health effect studies identified in the search and screening processes described in Section 2.2, without regard to magnitude or direction of study results, were considered for use in assessing the evidence for health effects associated with inhalation exposure to formaldehyde. In addition to the evaluations of the individual health effect studies, systematic evaluations of individual mechanistic studies were conducted in relation to several important health domains when this information could contribute to judgments about the human and animal evidence or hazard conclusions (discussed below). Individual study evaluations for literature on exposure, toxicokinetics, and some types of mechanistic data (e.g., in vitro studies) were not systematically conducted and documented. The study evaluations were used to inform the interpreted reliability of the study findings and whether those findings are likely to be caused by formaldehyde exposure alone.

Study methods were evaluated to assign a level of confidence in the results of the study with respect to the hazard question under consideration. The study confidence levels were high, medium, and low confidence, and not informative, and are presented as italicized text in the body of the assessment (Table 2-20). These evaluations were performed on a health outcome-specific basis, rather than a study-specific basis; thus, a single study was sometimes evaluated multiple times for different endpoints, using endpoint-specific considerations. High confidence studies generally had no notable methodological limitations for an outcome, while medium confidence studies were considered well conducted but had specific issues that might introduce a minor amount of uncertainty about attribution of the results solely to formaldehyde exposure. Methodological limitations of low confidence studies are considered to be significant, but the outcome-specific results might still be of limited use (e.g., as support for observations from other studies; to identify potential data gaps).

Table 2-20 Confidence classification definitions

Confidence Classification | Definition
High Confidence; (highly informative, with no notable limitations) | - No notable concern for bias, AND; - No notable methodological limitations, AND; - Study design is highly informative^a^ for the outcome in question, AND; - Analyses were appropriate and robust (observational studies)
Medium Confidence; (informative, with minor limitations ^b^ ) | - Minor uncertainty regarding bias or methodological limitations AND; - Study design and analyses were informative for the outcome in question
Low Confidence; (minimally informative, with major limitations) | - Methodological uncertainties or limitations are significant, but the study results might still be of limited use (e.g., as support for observations from other studies; to identify potential data gaps) OR; - Bias is apparent or other study aspects reduced sensitivity
Not Informative; (not used, critically deficient) | - Major concerns exist regarding methodological limitations that are expected to be a driver of study results or cause an unacceptably increased risk of bias, OR; - Description of methods, exposure levels or range, and/ or results were not adequate to enable a complete evaluation (observational studies), OR; - Experimental design is noninformative for the outcome in question (experimental studies)

a For experimental animal studies, considerations for whether the experimental design is informative include the sensitivity and specificity of the methodological approaches for informing the outcome in question, based on known or expected biology and common practice. These considerations include, but are not limited to: appropriateness and sufficiency of exposure timing and/or duration to allow for the outcome to be affected; sensitivity and specificity of the endpoint assays regarding their ability to detect subtle changes in the outcome; and how well the tested animals (e.g., based on what is known about insensitive species, strains, or sexes) are able to reveal the outcome (note: the human relevance of the response is not considered at this point).

b As the expectation is that experimental studies should attempt to control all variables, any study limitation capable of influencing the data was considered to have negatively affected the reliability of the results. Studies were categorized as medium confidence if they had specific issues which introduce a limited amount of uncertainty regarding the interpretation of the results as solely attributable to formaldehyde inhalation exposure.

The evaluations for studies identified as not informative are documented in Appendix B.3, but these data have no influence on assessment decisions and are not discussed in any detail in the Toxicological Review. In general, if a study or individual analysis (e.g., when multiple health outcomes or cohorts were assessed) was judged to have multiple severe limitations, or if reporting deficiencies precluded the ability to conduct an evaluation, it was concluded to be not informative. When potential limitations were identified, the evaluations considered the anticipated direction (i.e., bias toward or away from the null) and magnitude of the impact of the limitation(s) on the study results (when possible). Emphasis was placed on discerning limitations that would be expected to produce a substantive change in the results.

The evaluations used a domain-based approach focused on potential sources of bias or other limitations (including reduced sensitivity) that can affect the validity or interpretation of a study’s results. Thus, the confidence conclusions for individual studies reflect an interpretation of the reliability of the study results for answering each hazard question. The general procedure involved evaluating specific methodological features within different domains (categories) defining the potential areas of concern (different types of risk of bias and areas of potential insensitivity), although the categories differed between observational epidemiological, animal toxicological, and human-controlled exposure studies (see subsections below for discussion by study design, noting that the approach for mechanistic studies differs). Specific criteria for each domain developed for each health effect category (see Sections 2.3.2–2.3.10) were evaluated by two or more reviewers based on expert judgment of each study’s details to agree on a rating of good^8^, adequate, or deficient for each domain (see Table 2-21).

Table 2-21 Domain rating definitions

Domain Rating | Definition
Good | No notable uncertainties or limitations regarding study methodology
Adequate | Minor uncertainties or limitations interpreted as unlikely to have a notable impact on study results or their interpretability
Deficient | Serious uncertainties or limitations interpreted as likely to have a notable impact on the study results or their interpretability

Confidence classifications were determined for each study by integrating ratings of good, adequate, or deficient across domains. These determinations were not prescriptive, but rather were based on expert judgment. However, high confidence studies generally had good ratings for most or all domains with no deficient domain ratings; medium confidence studies generally had one or more adequate domain ratings interpreted to warrant reducing confidence, or a single deficient domain rating interpreted as unlikely to substantially affect results; low confidence studies typically had one or more deficient ratings interpreted as likely to affect the results or their interpretability; studies classified as not informative had one or more deficient ratings of notable concern, or multiple deficient ratings of lesser concern, which were judged to make the study results unusable.

Appendix B.3 contains summary evaluation tables developed for studies in each health effect category, which provide the relevant study characteristics and other information relating to evaluation of each domain, and overall confidence classification, with justifications as described for each study type (e.g., epidemiology; experimental animal) in the Appendix. In some situations, in which key study details or results were not presented, the study author(s) were contacted to obtain this information. Any additional study details obtained from the authors are noted in the evaluation summary tables and evidence tables.

The confidence classifications and primary drivers of those classifications are presented for the studies discussed in the evidence synthesis sections in the tables summarizing the evidence for each health effect. The evidence syntheses (Section 3; see methods in Section 2.5) and assessment conclusions (i.e., for hazard identification and dose-response analysis) focus on high and medium confidence studies, if available. Low confidence studies are less impactful to the evidence syntheses (and thus their discussion is minimized when higher confidence studies are available) and studies that are not informative are not impactful to any assessment decisions, and thus are not discussed in any detail.

#### Observational Epidemiology Studies: Evaluation Criteria and Classification Scheme

For each type of health outcome examined, the epidemiological studies were evaluated for information relevant to internal validity (bias) that could lead to an under- or overestimate of risk and to other features that could affect the interpretation of the results or limit the ability to detect a true association (e.g., narrow exposure range). The potential for selection bias, information bias (relating to exposure measurement and levels, and outcome ascertainment), confounding, and other details of the analysis and presentation of results were evaluated, alongside the application of considerations related to study sensitivity, and an overall confidence classification was developed for each study (or for a specific analysis within a study). For each evaluation domain, Table 2-22 describes the preferred study characteristics (i.e., supporting a “good” rating for that domain). The outcome-specific evaluations consider the methodological conduct of each study against these general preferences, also considering the health effect-specific considerations for evaluating each domain (see Sections 2.3.2−2.3.10), to rate each domain based upon the number and severity of the uncertainties and limitations identified, as previously described. For the documentation of the epidemiology study evaluations in Appendix B.3, domains with uncertainties or limitations leading to a low confidence classification are gray shaded; this shading is carried over to the evidence syntheses.

Table 2-22 Evaluation domains for epidemiology study evaluation

Evaluation domain | Preferred study characteristics (i.e., “Good” rating)
Population Selection | Recruitment, selection into study, and participation independent of exposure status and reported in sufficient detail to understand how subjects were identified and selected; recruitment or selection process unlikely to lead to inflated or attenuated effect estimate.
Information Bias: Exposure | Exposure assessment methods allow characterization of exposure within the etiologically relevant period for the outcome under study. See detailed description of exposure considerations below.
Information Bias: Outcome | Validated instrument for data collection; validation described, or citation provided; sensitive and specific outcome assessment. Ascertainment conducted without knowledge of exposure status.
Potential for Confounding | Important potential confounders addressed in study design or analysis. Potential confounding by relevant co-exposures addressed.
Analysis | Appropriateness of analytic approach given design and data collected; consideration of alternate explanations for findings; presentation of quantitative results.
Other Sensitivity Considerations | Sensitivity of study (exposure levels and contrast, duration of follow-up, sample size or number of cases^a^.

a Sample size alone is not used to judge a study as not informative.

Like all other studies, the synthesis of evidence from epidemiology studies focuses on the high and medium confidence studies, if available, taking into account differences in populations and settings (e.g., children and adults; occupational, residential, or in schools), exposure levels, and other aspects of the studies.

All residential or school-based studies with measures of formaldehyde exposure were included in the hazard identification evaluation. Because the database of studies with direct measurements is relatively large, residential studies with indirect measures of formaldehyde exposure (e.g., based on age of building or presence of plywood) were not included. Most of the included studies attempted to estimate average formaldehyde levels using area samples placed in one or more locations, with measurement periods ranging from 30 minutes to > 2 months. A few studies included more than one sampling period (i.e., sampling on multiple days in different seasons over the course of a year). Studies in adults and in children indicate that area-based (e.g., residential or school) samples are highly correlated with personal samples (Lazenby et al., 2012; Gustafson et al., 2005); therefore, the use of measures based on residential (e.g., bedroom) samples rather than personal samples was not considered to be a limitation when evaluating a study. Formaldehyde concentrations have been found to be uniform throughout the home in both standing housing stock and mobile homes (Stock, 1987; Sexton et al., 1989; Quackenboss et al., 1989c; Dally et al., 1981; Clarisse et al., 2003). Therefore, associations have generally been analyzed using a specific room measurement or household average concentrations.

The focus of the evaluation of exposure assessment was to determine the confidence that the methods used characterized exposure that occurred during the etiologically relevant period for the health outcome being reviewed. The validity of the measurement of average formaldehyde concentration was assessed by reviewing the description of sampling methods provided in each study. Indoor average formaldehyde measurements may be influenced by humidity and temperature, season, number of rooms sampled, sample placement, ventilation, and specific sources of formaldehyde in the building (Salthammer et al., 2010; Dannemiller et al., 2013). For chronic health outcomes, longer sampling periods (e.g., 1- to 2-weeks duration) were considered to be reflective of usual average exposure levels experienced by occupants. Studies have shown that formaldehyde levels remain relatively stable over a series of days or weeks (Stock, 1987; Quackenboss et al., 1989c; Hodgson et al., 2000; Gustafson et al., 2005), and reasonably represent longer term ongoing exposures. Concentrations are also correlated with season, which reflects the influence of temperature and humidity (Jarnstrom et al., 2006; Dannemiller et al., 2013; Clarisse et al., 2003). Within-person variability increases with shorter sampling durations (Gustafson et al., 2005). However, indoor formaldehyde concentrations have not been found to be associated with indoor combustion sources, such as active smoking or ETS exposure, or cooking with gas stoves or wood burning (Stock, 1987; Mullen et al., 2015; Hanrahan et al., 1984; Gustafson et al., 2005; Dannemiller et al., 2013; Dally et al., 1981; Clarisse et al., 2003).

Study evaluations looked for information regarding factors that influence formaldehyde levels as well as quality control measures and/or citations for exposure protocols. The following characteristics were examined to assess the potential bias and informativeness of the exposure measures in the observational epidemiology studies of formaldehyde in residences and schools:

- Duration of exposure measurement period and number of sampling occasions.
- Consideration of temperature, relative humidity, and a discussion of quality control.
- For shorter exposure periods (< 1 day), details regarding measurement protocol (e.g., shutting windows).
- Limit of detection (LOD) and percent <LOD.
- Ability to examine variability in risk in relation to variability in exposures above 0.010 mg/m^3^; the ability is based on the distribution of exposure, specifically the upper portion of the distribution (e.g., 75^th^ percentile) or the range of exposure encompassed within the study population (e.g., the degree of contrast between “high” and “low” exposure). A study that does not include values above 0.010 mg/m^3^ would not be able to detect variation in risk in relation to variation in exposure typically seen in indoor settings.^9^
- Information about the distribution of formaldehyde encompassed by the study (at least one descriptive statistic, preferably denoting a point on the upper part of the distribution such as the 75^th^ or 95^th^ percentile). EPA’s analysis is based on a comparison across studies of results, taking into account exposure levels; thus, it is not possible to interpret the results of a study that does not indicate the exposure levels that are being studied.
- The study design per se does not in itself determine the validity of the exposure assessment. That is, retrospective, concurrent (i.e., cross-sectional), or prospective designs can produce either high confidence or low confidence results, depending on the exposure measure and outcome under study. Even in cross-sectional designs, although exposure and outcome measurement may occur during the same time period, the exposure assessment can be retrospective, i.e., representing exposures that occurred prior to the change in health status. EPA carefully considered the etiologically relevant exposure period where exposure to formaldehyde could result in changes in health status for each outcome under review. For example, average levels of formaldehyde in a home or classroom during the previous several weeks and months was concluded to be the etiologically relevant periods for measures of current pulmonary function status or asthma episodes in the past 12 months. Exposure assessment protocols that included measurements of 5−7 days or more were considered to be “good” estimates of average ongoing exposure for this period of time. The residential exposure measurement protocol used in Krzyzanowski et al. (1990), consisting of two one-week samples, some taken in different seasons, in multiple locations in the home, used for assessment of current pulmonary function status as well as history of respiratory symptoms in the past 12 months, is an example of this category. In contrast, a 2-hour exposure measurement sample was considered “deficient” for outcomes with an etiologically relevant window measured in the past 12 months, concurrently, or in the subsequent 12 months. The 2-hour residential (bedroom) exposure measurement protocol used in the Norback et al. (1995) study of asthma and pulmonary function is an example of the “deficient” exposure measurement category.

A primary consideration in the evaluation of the occupational studies is the ability of the exposure assessment to reliably distinguish among levels of exposure within the study population, or between the study population and the referent population. A large variety of occupations are included within the studies; some represent work settings with a high likelihood of exposure to high levels of formaldehyde, and some represent work settings with variable exposures and in which the proportion of people exposed is quite small. In the latter case, the potential effect of formaldehyde would be “diluted” within the larger study population, limiting the sensitivity or informative nature of the study.

A variety of different approaches to the assessment of occupational exposure were used. These ranged from more specific, highly informative measures such as estimates of job-exposure matrix (JEM)-based TWA concentrations (based on job-specific formaldehyde measurements and the proportion of time spent at the job reported by participants) to measures subject to greater misclassification error, such as the self-reported use of specific products or chemicals, or assignment to exposures by supervisors.

Exposure assessments in some occupational studies involved one or more area samples in specific task areas, personal samples, or a combination of both. Sampling periods ranged from less than 1 hour to an entire work shift over 1 or more days. Concentrations were reported as an average over all samples for a particular location or as a time-weighted average (TWA) over the sampling period. Generally, a TWA concentration from a full shift measurement using personal sampling was considered a more precise estimate of exposure. Some occupational groups (e.g., carpenter, embalmer, pathologist) or industry (e.g., production or use of formaldehyde resins, wood-products, paper, textiles, foundries) were considered to be highly exposed to formaldehyde and were included despite the absence of sampling data.

Some studies may have documented formaldehyde exposures using exposure monitors or quantified the absolute or relative exposure for different tasks, which may be matched to individual occupational patterns using “job exposure matrices” or JEMs. The following characteristics were examined to assess the potential bias and informativeness of the exposure measures in studies based on occupational history:

- Consideration of long-term and short-term job history with industry, occupation, and task details.
- Use of formaldehyde monitoring data to allow assessment of intensity and frequency of exposure.
- Completeness of occupational history for the relevant time period for a given outcome (e.g., 20+ years preceding diagnosis for cancer and ALS; pre-conception and during pregnancy for studies of spontaneous abortion; recent job history prior to neurobehavioral testing).
- Validation of JEM using formaldehyde measurements and industry, occupation, and task details specific to the study location.

As previously indicated; studies that evaluated more than one outcome might be classified differently for each outcome. The classification of a study could also vary among different analytical groups or analytic strategies within a study (e.g., studies of children and adults, with separate analyses for each group), depending on the information presented for the different analyses. In addition, and primarily for low confidence studies, when sufficient information was available, the potential direction of bias (i.e., a low confidence study with a likely over-estimation of the effect estimates) is documented and discussed.

#### Experimental Studies in Animals: Evaluation Criteria and Classification Scheme

Toxicological studies in animals differ systematically from observational epidemiological studies because the former seek to control both the exposure and nonexposure conditions of an experiment. This leads to some differences in approach and interpretation. In general, however, toxicological study evaluations in animals considered similar categories to the epidemiological studies. In addition to exposure quality, the categories were based on the design of a toxicological study, including test animals, experimental design (e.g., duration of exposure, timing of endpoint evaluations, allocation procedures), exposure conduct, endpoint evaluation procedures, and data presentation and analysis. The specifics of the considerations applied within each evaluation domain were different for each type of health outcome examined. As the expectation is that experimental studies should attempt to control all variables, any study limitation interpreted as capable of influencing the data was considered to have negatively affected the quality (e.g., validity, accuracy) of the results. Thus, potential “confounders” in experimental studies (i.e., any uncontrolled variable capable of influencing the results) differ fundamentally from what would be deemed a potential “confounder” in epidemiological studies (the latter of which must be associated with both the exposure and the outcome).

For each evaluation domain, Table 2-23 describes the preferred study characteristics (i.e., supporting a “good” rating for that domain). The outcome-specific evaluations consider the methodological conduct of each study against these general preferences, also considering the health effect-specific considerations for evaluating each domain (see Sections 2.3.2−2.3.10), to rate each domain based upon the number and severity of the uncertainties and limitations identified, as previously described. These evaluations were conducted for each independent “experiment” (i.e., a cohort of exposed animals assessed for an endpoint or set or related endpoints). The documentation of the animal study evaluations uses symbols and shading to present the domain specific ratings in Appendix B.3 (i.e., Good = ++; Adequate = +; Deficient = gray shading); this shading is carried over to the evidence syntheses (i.e., gray shading reflects a classification of low confidence). Additional considerations that might influence the interpretation of the usefulness of the studies during the hazard synthesis are noted in the Appendix study documentation tables and evidence synthesis. Depending on the specified health effect-specific study evaluation criteria, factors falling outside the specified scope of review could include limitations such as a short exposure duration or the use of only one test concentration or concentration that are all too high or too low to provide a spectrum of the possible effects, as well as study strengths such as very large sample sizes, use of good laboratory practices (GLP), or particularly robust endpoint protocols; however, this information generally did not affect the study confidence classifications themselves.

Table 2-23 Evaluation domains for experimental animal study evaluation

Evaluation domain | Preferred study characteristics (i.e., “Good” rating)
Exposure Quality | Studies should apply and document appropriate methods for the seven elements of inhalation exposure quality (the most notable elements for this assessment are: test article characterization, controls, and chamber type)
Test Subjects | The species, strain, sex, and age are appropriate and sensitive for the endpoint(s) of interest; no overt systemic toxicity is noted or expected; and allocations can be inferred as appropriate, considering matching across groups at onset of experiment; the sample size provides reasonable power to assess endpoint(s) in question^a^.
Study Design | The design of the experiment is appropriate, reproducible, and sensitive for the endpoint(s) of interest, including a sufficient exposure duration and appropriate timing of endpoint evaluations; lack of additional variables introduced over the course of the study that would be expected to modify the results (no “confounding factors” introduced).
Endpoint Evaluation | The methods used to assess the outcome are sensitive, complete, discriminating (specific), and biologically sound (reliable); experimenter bias is minimized.
Data considerations and statistics | The statistical methods are reported^b^, group comparisons and data (including variability) presentation are appropriate and discerning; results for all endpoints evaluated in the study are presented (lack of selective reporting)

a Sample size alone is not used to judge a study as not informative.

b During study evaluation, the focus for reviewing statistical methods is on transparent reporting as EPA may decide to conduct additional or alternative statistical analyses as part of data extraction or evidence synthesis.

Overall, as in observational studies in humans, considerations related to the quality of the exposure paradigms used in experimental studies typically had the strongest influence on study confidence determinations. As experimental studies should aim to control all variables other than the exposure or manipulations of interest, coexposure to methanol introduces uncertainty that the effects were caused by formaldehyde alone. Inhaled methanol could affect health endpoints or introduce quantitative uncertainty. Highly reactive formaldehyde is mostly captured in the nose, the main site of formaldehyde-induced lesions, and very little enters the blood stream. Conversely, methanol mostly bypasses the nose but is readily absorbed in the lungs and then distributed to distal sites, including the blood and other nonrespiratory tissues, where it can be metabolized to formaldehyde. Since inhaled methanol can be distributed to different locations than inhaled formaldehyde, it could either directly cause effects or, theoretically, be metabolized to formaldehyde and cause effects in tissues that are not a target of inhaled formaldehyde. In addition, because methanol is metabolized to formaldehyde in vivo, substantial coexposure to methanol could result in differences in tissue-specific formaldehyde levels at identical external formaldehyde exposure levels when different test articles are used. This limitation is expected to introduce a bias toward an effect and is of particular concern in studies evaluating non-portal-of-entry effects. Thus, conclusions about the level of uncertainty introduced by this coexposure varied by health outcome, with a far greater level of concern for potential impacts on nonrespiratory health effects (Section 3.3), as compared to respiratory health effects (Section 3.2). This disproportionate level of concern is primarily based on two factors: (1) as compared to formaldehyde, which does not appear to be distributed to distal sites in appreciable amounts, inhaled methanol would be readily transported beyond the portal of entry (POE) and could elicit direct effects at distal target tissues, and (2) certain systemic effects evaluated in this assessment (i.e., reproductive and developmental toxicity, nervous system effects) are health outcomes known to be a target of methanol toxicity, while other health outcomes, although generally less well studied, have not been clearly associated with methanol exposure (U.S. EPA, 2013). These issues are discussed further in each major endpoint discussion in Section 3.

For certain health outcomes, the irritant and odorant nature of formaldehyde gas and the inescapable nature of these exposures (animals cannot terminate exposure at irritating levels), can complicate interpretations of causality. In addition, reflex bradypnea is an irritant response that exists in rodents, typically at formaldehyde concentrations exceeding 1 mg/m^3^ (see Appendix C.2), but not humans, and can cause large variations between the administered and internal exposures. Although the understanding of irritation-related responses, including reflex bradypnea in rodents, is incomplete (e.g., responses following repeated and prolonged exposure are not well studied), it is generally assumed that irritation- and odorant-specific changes are either short lived or markedly reduced shortly after formaldehyde exposure is removed. In light of these considerations, care was taken to consider in detail the specifics of the study protocols related to formaldehyde exposure (e.g., determining whether a sufficient duration was allotted between exposure and testing, evaluating whether the exposure levels tested were capable of introducing variables such as reflex bradypnea) for certain health outcomes, particularly for the evidence syntheses of potential nervous system effects (Section 3.3.1) and developmental and reproductive toxicity (Section 3.3.2).

Inhalation toxicity studies are particularly challenging because of the inherent complexity of generating and characterizing consistent chamber atmospheres. Poor study design, human error, and problems with mechanical and electronic equipment can impair an inhalation exposure and undermine the validity of a study. In experimental studies, there is an expectation that test subjects in an inhalation chamber study will be exposed solely to a well-characterized test article under conditions that are carefully regulated, frequently measured, and clearly reported. When a chamber study is conducted under GLP standards, there is typically greater certainty that all aspects of that study were properly performed and documented.

Experimental inhalation studies were evaluated by two or more scientists familiar with inhalation chamber operations for seven key elements of exposure quality:

1) Test Article Characterization: The test article is the substance or mixture of substances to which humans or animals are exposed. Any substances used to generate the test article should be well characterized. For example, formaldehyde gas can be produced by heating paraformaldehyde, formalin, UFFI insulation, or Delrin plastic. The test article description should ideally include its physical nature (solid, liquid, gas, etc.), purity, CAS registry number (if known), and physicochemical properties (including isomerization and radiolabeling). Because inhaled methanol (but not formaldehyde) is systemically distributed and can cause neurological and developmental effects, a methanol control group is desirable for studies of commercial formalin, typically contains methanol as a stabilizer. Only 2 of 84 studies known or believed to have tested commercial formalin included methanol controls.
2) Controls: A concurrent negative (air) control group should be used in inhalation toxicity studies. The test chamber, itself, is considered an experimental variable that should be controlled.
3) Generation Method: The equipment and method used to generate a chamber atmosphere should be clearly described. If methods from another publication are cited, the methods in the secondary article were evaluated (if accessible). Given the simplicity of generating a test atmosphere of formaldehyde, a deficiency in this element was not considered to represent a notable limitation for this assessment. Greater weight was applied to the test article used to generate the atmosphere (above).
4) Analytical Method: The method used to measure test atmospheres should be clearly described and suitable for the test chemical. There are specific methods (e.g., direct sampling, adsorptive, or chemical reactive methods, and subsequent analytical characterization such as HPLC, gas chromatography, etc.) and nonspecific methods such as gravimetric filter analysis. In addition, a real-time monitoring device (e.g., an aerosol photometer for aerosols or a total hydrocarbon analyzer for gases or vapors) may be used to monitor the stability of chamber atmospheres.
5) Analytical Concentrations: Every chamber study should report three concentrations, which are listed in the order of their usefulness:
  - The analytical concentration is the analytically measured concentration of a substance to which test subjects are exposed in their breathing zone. Because analytical concentrations are recorded throughout the course of a chamber study, they can reveal generation problems, fluctuations in chamber levels, analytical problems, and missed exposures. If analytical concentrations are not reported for a study considered for use in quantitative analyses, an effort should be made to acquire them from the study authors, as analytical concentrations are preferred when deriving an RfC. The use of target or nominal concentrations to derive an RfC should be cited as a study limitation, although nominal concentrations are considered accurate for gases (but not vapors).
  - The nominal concentration is the mass of generated test article divided by the total volume of air passed through the chamber. Nominal and analytical concentrations for gases are usually quite close. Conversely, the nominal concentration for a vapor or aerosol is typically greater than the analytical concentration (sometimes orders of magnitude greater) due to test chemical clumping, precipitation, and/or deposition on chamber walls and plumbing.
  - The target concentration is the concentration the study director hopes to achieve in a chamber study (e.g., 1, 3, and 10 mg/m^3^). Because a target concentration is a goal—not a measurement—one should not assume that test subjects were actually exposed at the precise target concentrations.
  - Some fluctuation in analytical chamber concentration is expected, but concentrations should deviate from the mean chamber concentration by no more than ±10% for gases or vapors or ±20% for liquid or solid aerosols (GD 39 (OECD, 2009)). Excessive atmosphere fluctuation is evidence of a test article generation problem.
  - The lack of reporting of analytical concentrations alone (no other deficiencies) was considered a minor limitation (i.e., an adequate rating overall).
6) Particle Size Characteristics: Particle median diameter, density, and distribution (geometric standard deviation or σg) should be characterized whenever test subjects may be exposed to an aerosol or to a vapor that may condense into inhalable aerosol particles. Particle sizing is not necessary when testing a gas. The mass median aerodynamic diameter (MMAD) is often calculated, but metrics such as physical diameter, median particle number, or surface area may also be evaluated as the most relevant metric. This element was not important for formaldehyde.
7) Chamber Type: Inhalation chambers are either dynamic or static. Dynamic chambers, which include nose-only, head-only, and whole-body chambers, have a constant flow of filtered air and consistent test article concentrations, but static chambers do not. EPA and OECD inhalation test guidelines indicate use of a dynamic chamber. Static chamber studies are not preferred for longer term hazard identification or exposure response analyses in particular, as they can lead to a harmful buildup of by-products (e.g., CO_2_). Consideration should also be given to whether the test article is best delivered by whole-body or nose-only chambers. Animals exposed to an aerosol in a whole-body chamber may receive a significant oral exposure due to preening of particles deposited on their fur. To prevent this, nose-only chambers are recommended when testing aerosols and vapors that may precipitate into particles.

The documentation of the exposure quality assessment for controlled exposure studies is included in Appendix B.3.1 (note: the evaluations of elements #1 and #2 are documented together) and then summarized as one (very influential) domain of the health effect-specific documentation of study evaluations by health effect in Appendix B.3 and the syntheses (Section 3).

#### Controlled Exposure Studies in Humans: Evaluation Criteria and Classification Scheme

A process incorporating aspects of the evaluation approaches used for epidemiological studies and experimental animal studies (see below) was used to evaluate controlled exposure studies in humans. Controlled human exposure studies were evaluated for important attributes of possible bias and the appropriateness of the study design for the outcome(s) of interest. For each evaluation domain, Table 2-24 describes the preferred study characteristics (i.e., supporting a “good” rating for that domain). The outcome-specific evaluations consider the methodological conduct of each study against these general preferences, considering also the health effect-specific considerations (see Sections 2.3.2−2.3.10), to rate each domain based upon the number and severity of the uncertainties and limitations identified, as previously described.

Table 2-24 Evaluation domains for controlled exposure studies in humans

Evaluation domain | Preferred study characteristics (i.e., “Good” rating)
Exposure Assessment | Domain considerations applied to experimental animal studies regarding the conduct of the inhalation exposures were applied, including inclusion of a clean air control exposure and other aspects of the exposure protocol. For example, a study was judged to be low confidence if the exposure generation method resulted in exposure to substances other than formaldehyde (e.g., emissions from pressed wood products).
Outcome Classification | Appropriateness of the timing and methods used to evaluate the outcome(s) of interest.
Consideration of Potential (Observer and Subject) Bias | Specifically, randomization and blinding of subjects and investigators. In general, low confidence was applied if allocation to the order of exposure categories was not random, or subjects were not blinded to their exposure order; however, when studies evaluated multiple dose levels, an important strength for the hazard assessment, they were judged as medium confidence when reporting detail was the only identified limitation (e.g., the authors did not describe the measures used to control bias).
Consideration of Likely Confounding | Important potential confounders addressed in study design or analysis; lack of additional variables introduced over the course of the study that would be expected to modify the results.
Results Presentation | The group comparisons and data (including variability) presentation are appropriate and discerning; results for all endpoints evaluated in the study are presented (lack of selective reporting).
Size | The evaluation of few individuals (generally n ≤ 10, considering the endpoints evaluated) resulted in reduced confidence^a^.

a Sample size alone is not used to judge a study as not informative.

#### Mechanistic Studies: Approach and Evaluation Criteria

For this assessment, in multiple instances where a reasonable number of studies were available, but the mechanistic interpretations were not well-established, the individual mechanistic studies were systematically evaluated. For evaluations of individual mechanistic studies in experimental animal studies or in vitro models of gaseous formaldehyde exposure (i.e., mechanistic studies related to respiratory effects; mechanistic studies of formaldehyde inhalation related to nervous system effects and developmental and reproductive toxicity) the same general features evaluated for more apical measures of toxicity were considered (i.e., evaluations of exposure quality and study design were emphasized), although the specific criteria were simplified to accommodate the increased heterogeneity of the available mechanistic studies as compared to more traditional, apical measures of toxicity. Similarly, study evaluations of individual human studies (i.e., mechanistic studies related to respiratory effects; human studies of genotoxicity endpoints) emphasized consideration of exposure assessment, study design, outcome ascertainment, and comparison groups for potential sources of bias and their potential impact. While these individually evaluated studies represented the totality of the evaluated mechanistic information for some health effect-specific evaluations (most of the noncancer health effects), several other health effect-specific mechanistic analyses (e.g., respiratory tract pathology; cancer MOA) considered subsets of these individually evaluated studies alongside other information, including sets of studies that were not individually evaluated (e.g., while human genotoxicity studies were individually evaluated, the myriad animal and in vitro studies of genotoxic endpoints were not). In these latter cases, the body of evidentiary support (or lack thereof) for specific, influential mechanistic events (e.g., those known to be associated with the health outcome of interest; those previously implicated in authoritative reviews as relevant to interpreting formaldehyde exposure-induced health effects) were considered in totality, with judgments based on overarching interpretations across the different sets of inter-related studies. Additional details on these approaches are provided in Sections 2.3.6 and 2.3.10.

### 2.3.2 Sensory Irritation Study Evaluation Criteria

The literature search for sensory irritation focused on identifying relevant studies in humans (see Section 2.2.2). Evaluations of individual mechanistic studies conducted as part of the overarching review of mechanistic information related to noncancer respiratory effects emphasized consideration of issues related to exposure conduct, as described elsewhere (see Section 2.3.6 and Appendix B.3.6). All human studies identified by the literature search for sensory irritation that met the inclusion criteria as described in Section 2.2.2, were evaluated, and classified by confidence level. Tables that document the evaluation of human studies are found in Appendix B.3.2, including both the identified observational epidemiology studies and the studies of controlled human exposure.

#### Human Observational Epidemiology Studies

Table 2-25 provides criteria used to evaluate the domains for each observational epidemiology study of sensory irritation.

Symptoms related to irritation of the eyes, nose, and throat were reported by most studies. Generally, symptoms were ascertained via self-report or through interviews, both using a standardized questionnaire (e.g., American Thoracic Society [ATS]). Self-reported symptoms may be influenced to some degree by recall bias if exposure is known to the responder, although this is of less concern if an appropriate comparison is used. For some studies, there were more serious concerns about selection or information bias related to the participants’ knowledge of their exposure or selection into a study based on presence of symptoms and concerns about exposure, which could produce spurious findings (Wei et al., 2007; Salonen et al., 2009; Ritchie and Lehnen, 1985, 1987; Norsted et al., 1985; Dally et al., 1981; Bracken et al., 1985). The studies of residential formaldehyde exposure included a wide range of ages (adults and children) and potentially susceptible individuals, some of whom had existing respiratory issues and other health conditions, and thus, in general, concerns regarding potential insensitivity of the study population did not apply.

The time frame of the exposure assessment relative to the assessment of symptoms was an important aspect of the evaluation of symptom prevalence. The relevant period for the assessment of irritant responses was considered to be concurrent with the time period of the exposure assessment because the symptoms associated with irritation occur immediately (Krakowiak et al., 1998; Andersen, 1979; Andersen and Molhave, 1983). Questions about symptom occurrence over an extended time period (weeks and months) that were separated in time from the exposure assessment period were considered to be more limited by recall bias. Some of the studies of anatomy students assessed symptoms of irritation that occurred during lab sessions several weeks or months previously, which increased concern regarding recall bias. The occupational studies generally ascertained the prevalence of symptoms while at work via interview using standardized questionnaires.

Table 2-25 Criteria for domain ratings in epidemiology studies of sensory irritation

Evaluation domain | Primary criteria for domain ratings
Evaluation domain | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Population (SB) | General population: Participant selection based on population-based sampling frame with high participation rate.; Occupational settings: High participation rate but potential for “healthy worker effect” to lead to attenuated effect estimate. | Uncertainty regarding participant recruitment process or participation rate. | General population: Participant selection based on exposure status.; Occupational settings: Recruitment process or self-selection likely to lead to inflated effect estimate.
Exposure (IB) | General population: Exposure measurements designed to characterize average concentrations in a residence over a defined period with details regarding measurement protocol (e.g., shutting windows).; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure.; All settings: Exposure window should reflect the same period as the characterization of symptoms. | General population: Details regarding measurement protocol provided, but uncertainty regarding characterization of average residential concentrations corresponding to the period of outcome assessment.; Occupational settings: Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates) | All settings: Large percentage (e.g., 50% or higher) of measures < LOD, or other ways in which exposure range does not allow meaningful analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.
Outcome (IB): | American Thoracic Society (ATS) questionnaire or other validated questionnaire for irritation symptoms. Symptoms reported without knowledge of exposure status. | Instrument or methods for data collection less well described. Symptoms reported without knowledge of exposure status, or knowledge unlikely in light of exposure levels or range. | Symptoms reported with knowledge of exposure status. Instrument or methods for data collection not described and uncertainty whether symptoms were reported without knowledge of exposure status.
Confounding (Cf) | Potential for confounding considered and addressed in design or analysis. Primary potential confounders were age, gender, smoking, and respiratory exposures associated with the outcomes that were correlated with formaldehyde. | Potential for confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with sensory irritation may remain. | Potential for confounding prevents differentiation of effect of formaldehyde from effect of other exposure(s).
Analysis and Other (Oth) | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. Data provided that allows characterization of the distribution of exposure, e.g., upper 75^th^ percentile. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.

#### Controlled Exposure Studies in Humans

Controlled human exposure studies were evaluated for important attributes of experimental studies, including randomization of exposure assignments, blinding of subjects and investigators, and inclusion of a clean air control exposure and other aspects of the exposure protocol. The evaluation of few individuals (n ≤ 10) resulted in reduced confidence. Several studies did not describe the measures used to control bias, resulting in a lower level of confidence in study results. However, some of these studies evaluated multiple dose levels, an important strength for the hazard assessment. Therefore, these studies were included with medium confidence when reporting detail was the only identified limitation.

### 2.3.3 Pulmonary Function Study Evaluation Criteria

The literature search for pulmonary function focused on identifying relevant studies in humans (see Section 2.2.3). Controlled exposure studies in humans were evaluated as described for sensory irritation endpoints in Section 2.3.2. Likewise, evaluations of individual mechanistic studies conducted as part of the overarching review of mechanistic information related to noncancer respiratory effects emphasized consideration of issues related to exposure conduct, as described elsewhere (see Section 2.3.6 and Appendix B.3.6). Thus, the discussion and criteria discussed below relate primarily to the identified observational epidemiology studies. The individual study evaluation decisions are documented in Appendix B.3.3.

Pulmonary function is assessed using spirometry, which measures the volume and speed of air that is exhaled or inhaled. Several parameters can be measured during spirometric testing to characterize an individual’s respiratory health (Table 2-26). The American Thoracic Society has published guidelines for equipment performance requirements, validation, quality control, test procedures, and reference equations for each type of spirometric measurement (Miller et al., 2005a; Miller et al., 2005b), as well as the interpretation of testing results (Pellegrino et al., 2005). Ratings in the outcome domain were highest when pulmonary function outcomes were measured using the guidelines published by the American Thoracic Society or providing a description of the protocols and reference equations that were used. In addition to the use of conventional spirometric equipment, peak expiratory flow has been measured in research settings using portable flow meters operated by study participants trained in their use. Although it requires careful training and monitoring, this method has the advantage that it can be used in large epidemiological studies and multiple measurements can be obtained over time (Tepper et al., 2012). Studies of residential exposure to formaldehyde were conducted in this way (Krzyzanowski et al., 1990; Kriebel et al., 2001).

Table 2-26 Common measures of pulmonary function reported in studies of formaldehyde inhalation

Measure | Definition
Vital Capacity (VC); (Liters at BTPS) | The volume of air between a full inspiration and maximal expiration (an unforced maneuver)
Forced Vital Capacity (FVC); (Liters at BTPS) | The maximum volume of air forcibly exhaled after a maximal inspiration
Forced Expiratory Volume, 1 second (FEV_1_); (Liters at BTPS) | The volume of air that is exhaled with maximal force in the first second
Forced Expiratory Flow; 25−75% (FEF_25−75_) (L/sec) | The mean forced expiratory flow in the 25th and 75th percentiles of FVC (also called maximum mid-expiratory flow [MMEF, MEF])
Ratio of FEV_1_ to FVC (FEV_1_/FVC) | Proportion of vital capacity exhaled in the first second of forced expiration
Peak Expiratory Flow Rate (PEF or PEFR); (L/sec at BTPS or L/min) | The maximum flow obtained from a person’s maximum forced expiration starting from the point of a maximal lung inflation

BTPS: Body temperature and ambient pressure saturated with water vapor.

Source: Miller et al. (2005a).

Pulmonary function varies by race or ethnic origin, gender, age, and height, and is best compared when normalized to the expected lung function based on these variables (Tepper et al., 2012; Pellegrino et al., 2005; Hankinson et al., 1999). Studies that did not adjust or otherwise account for these variables when comparing results between exposure groups were not considered. Pulmonary function also is associated with smoking status (Becklake and White, 1993), which was considered in the evaluation of potential confounding. FEV_1_ and PEFR exhibit diurnal variation, and this complicates the interpretation of changes across a work shift or during a laboratory session if no comparisons were made with an unexposed group (Lebowitz et al., 1997; Chan-Yeung, 2000). Studies with no comparison group were given less weight in evaluating study results.

The healthy worker effect and survivor (lead time) bias was a concern for several cross-sectional occupational studies, some of which had no other major limitations. Removal of individuals more sensitive to the irritant effects of formaldehyde from jobs or tasks with formaldehyde exposure likely occurred in industries with high formaldehyde exposures, and this type of selection bias might result in an attenuation of risk estimates or a null finding if these individuals also experienced effects on pulmonary function. Table 2-27 provides criteria used to evaluate the domains for each observational study of pulmonary function.

Table 2-27 Criteria for domain ratings in epidemiology studies of pulmonary function

Evaluation domain | Primary criteria for domain ratings
Evaluation domain | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Population (SB) | General population: Participant selection based on population-based sampling frame with high participation rate.; Occupational settings: High participation rate but potential for “healthy worker effect” to lead to attenuated effect estimate. | Uncertainty regarding participant recruitment process or participation rate. | General population: Recruitment process or self-selection likely to lead to inflated effect estimate.
Exposure (IB) | General population: For inferences above 0.050 mg/m^3^, exposure range includes large enough sample above 0.050 mg/m^3^ to allow for meaningful analysis in this range.; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure.; All settings: Exposure measure must reflect the etiologically relevant time window. For measures of average pulmonary function, average ongoing exposure experienced during the past several weeks or months. Exposure measure based on at least 5-d sample, or if < 5 days, measures in more than one season. For measures of change, exposure assessment occurring concurrently or representing average conditions prior to change. | General population: More limited exposure assessment than described in “Good” category (e.g., 1-5 days) with some details regarding measurement protocol.; Occupational settings: Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates).; All settings: Uncertainty regarding correspondence between measured levels and levels in the etiologically relevant time window. | All settings: Large percentage (e.g., 50% or higher) of measures < LOD, or other ways in which exposure range does not allow meaningful analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.; General population: Short (<1 d) exposure measurement period with no, or limited, discussion of protocol and quality control assessment.; All settings: Large percentage (e.g., 50% or higher) of measures < LOD, or other ways in which exposure range does not allow meaningful analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.
Outcome (IB) | Pulmonary function outcomes measured using American Thoracic Society guidelines or providing a description of the protocols and reference equations that were used. Methods described or reference provided for measures of peak expiratory flow. Outcome measurement conducted without knowledge of exposure status. | Instrument or methods for data collection less well described. | Instrument or methods for data collection not described. Symptoms reported with knowledge of exposure status.
Confounding (Cf) | Potential for confounding considered and addressed in design or analysis. Primary potential confounders were race, height, age, gender, smoking, and respiratory exposures associated with the outcomes that were correlated with formaldehyde. | Potential for confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with pulmonary function may remain. | Potential for confounding prevents differentiation of effect of formaldehyde from effect of other exposure(s).
Analysis and Other (Oth) | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. Data provided that allows characterization of the distribution of exposure, e.g., upper 75^th^ percentile. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.; [underlined: For changes across work shift or lab session:] No comparison to changes in an unexposed group during same time-period.

### 2.3.4 Immune-Mediated Conditions, Focusing on Allergies and Asthma, Study Evaluation Criteria

The literature search for immune-mediated conditions initially focused on identifying relevant studies in humans or animals (see Section 2.2.4), although the experimental animal studies were ultimately considered most appropriately analyzed as mechanistic evidence within the broader context of the review of mechanistic information for potential respiratory effects (see Section 2.3.6); thus, the documentation of the animal study evaluations is in Appendix B.3.6. The evaluation of observational epidemiology studies section is discussed below first, followed by a summary of the evaluation of controlled human acute exposure studies. Tables documenting the evaluation of each of the human studies in this section is found in Appendix B.3.4.

#### Observational Epidemiology Studies

EPA consulted with two panels of epidemiology experts to develop criteria to rate the confidence in the results for observational epidemiology studies of allergic response^10^ and of asthma.^11^ Each panel was given extracted information regarding case ascertainment or outcome classification from studies using questionnaire-based measures (or, for the allergy panel, skin prick tests). These studies were reflective of the most common study designs used, e.g., cross-sectional with concurrent assessment of exposure and of symptoms over a preceding period ranging from 4 weeks to 12 months. Descriptive information about the study population (e.g., size, age, country) was also provided but the material did not include any information regarding results for formaldehyde or other exposures.

The panels’ discussions and the criteria relating to the evaluation of outcome assessment are described below.

##### Ascertainment of allergic sensitization and allergies

Questionnaire-based ascertainments of nasal and ocular symptoms have been developed and widely used, for example in the International Study of Arthritis and Allergies in Children (ISAAC) (Asher et al., 1995). The additional ascertainment of seasonality and triggers can be helpful in distinguishing between allergic and nonallergic basis of the symptoms. When comparing specific types of self-reported allergies to specific types of positive skin prick tests, specificity of self-report is relatively high (approximately 90% or higher), but sensitivity is lower (ranging from 30−70%) (see for example (Lakwijk et al., 1998; Dotterud et al., 1995; Braun-Fahrländer et al., 1997)). Limiting case ascertainment to physician-diagnosed allergies increases specificity but is considered to have low sensitivity because self-treatment with nonprescription medications is common. Questionnaire-based ascertainments of atopic dermatitis or eczema have also been developed (Williams et al., 1996; Asher et al., 1995). These questionnaires focus on the extent, location, and itchiness of the rash and age at onset (typical onset before age 2 years). Specificity, compared to physician diagnosis, was high (>0.95) in school-age children (Williams et al., 1996) and in younger children (von Kobyletzki et al., 2013).

Based on advice from the expert panel, EPA considered cross-sectional designs using questionnaires for rhinitis or rhinoconjunctivitis to provide an adequate basis for case ascertainment in studies in Europe and the United States; in studies in other areas (i.e., areas that have not been included in ISAAC), specific mention of validation of the questionnaire was needed to receive a high confidence rating. Although the specificity of questions pertaining to rhinitis may be lower than the specificity of questions pertaining to rhinoconjunctivitis (Kim et al., 2012), based on the feedback received, this difference was interpreted by EPA as insufficient to conclude that the rhinitis questions should be viewed with lower confidence.

##### Ascertainment of asthma

Self- (or parent-) report of physician-diagnosed asthma can be reliably used in epidemiological studies of incidence of asthma, although this method can miss undiagnosed asthma. “Current” asthma, or prevalence of current asthma, is typically ascertained through a set of questions pertaining to symptoms or medication use over of period of time (e.g., last 12 months). A similar, but usually expanded, set of questions can be used to assess asthma control over a shorter period of time (e.g., 2−4 weeks). (Asthma control pertains to the extent to which symptoms can be reduced or eliminated with medication.) Asthma exacerbation is a term typically used in clinical trials and considers the need for using systemic corticosteroids.

Most of the studies identified in the formaldehyde literature are studies of prevalence of current asthma and used a classification scheme based on the American Thoracic Society (ATS) questionnaire (Ferris, 1978) or subsequent instruments that built upon this work, including the ISAAC and European Community Respiratory Health Survey (ECHRS) questionnaires. Based on consultation with the expert panel, these questionnaire-based approaches have been found to have an adequate level of specificity and positive predictive value for use in etiologic research (Ravault and Kauffmann, 2001; Jenkins et al., 1996; Burney et al., 1989) that focuses on the occurrence of episodes of asthma, as opposed to the first occurrence of asthma. The questionnaires typically use several questions to define current asthma based on symptoms relating to wheezing episodes or shortness of breath, reported history of asthma attacks, or use of asthma medication. As noted in the discussion of ascertainment of allergies, the questionnaires have been used in many studies but have not necessarily been validated in every population.

The age of study participants is an important consideration in the interpretation of various measures. Specificity of symptom questions is reduced in the very young (<5 years) because wheezing can occur with respiratory infections in infants and young children, and specificity is reduced at older ages (e.g., >75 years) because of the similarities in symptoms and medication use for chronic obstructive pulmonary disease and asthma (Taffet et al., 2014; Abramson et al., 2014).

Asthma can be atopic (allergic) or nonatopic. In the United States 1988−1994 NHANES data, 56% of self-reported physician diagnosed asthma cases had at least one positive skin prick test (Arbes et al., 2005). Thus, the delineation of asthma into these different groups can reduce some of the heterogeneity, but exclusion of either group may significantly reduce the sensitivity of case ascertainment.

Considering the expert advice and the considerations above, the eligible population for asthma was defined for the purposes of this assessment as “humans, age > 4 years” because the respiratory disorder occurring in infants and toddlers may be related to, but is distinct from, asthma, which is more reliably diagnosed in school-aged children. Thus, five studies initially identified as asthma studies in the literature search are not classified as studies of asthma in the assessment, but rather as studies of “lower respiratory tract symptoms in infants and toddlers” Raaschou-Nielsen et al. (2010) Roda et al. (2011) Rumchev et al. (2002). Li et al. (2019) Yu et al. (2017). Studies of asthma or asthma symptoms that included ages 3–4 within a larger cohort of older children were included if the proportion of the study group in the age range was likely to be relatively small (e.g., if the mean age was > 5 years).

##### Summary of Evaluation Criteria

Table 2-28 describes the criteria used for the domain ratings informing the confidence classifications for epidemiological studies of immune-mediated conditions.

Table 2-28 Criteria for domain ratings in epidemiologic studies of allergies and asthma

Evaluation Domain | Primary criteria for domain ratings
Evaluation Domain | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Population (SB) | General population: Participant selection based on population-based sampling frame with high participation rate.; Occupational settings: High participation rate but potential for “healthy worker effect” to lead to attenuated effect estimate. | Uncertainty regarding participant recruitment process or participation rate. | General population: Participant selection based on exposure status.; Occupational settings: Recruitment process or self-selection likely to lead to inflated effect estimate.; Asthma: Studies of infants and children < 5 years^a^
Exposure (IB) | General population: For inferences above 0.050 mg/m^3^, exposure range includes large enough sample above 0.050 mg/m^3^ to allow for meaningful analysis in this range.; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure.; All settings: Exposure measure should reflect etiologically relevant period.; Incidence of allergies (over subsequent 12 months) – or prevalence of allergy symptoms (in past 12 months or shorter period) - Exposure measure based on at least 5-d sample measures or fewer days if sampled in more than one season.; Allergy sensitization (skin prick tests) - exposure measure should reflect the period before or during which sensitization occurs.; Current asthma (in past 12 mos or shorter time period) Exposure measure based on at least 5-d sample measures or fewer days if sampled in more than one season.; Asthma control (symptoms and medication use over the past 2–4 weeks) - exposure measure concurrent with the outcome assessment.; Nighttime asthma symptoms, exposure measures taken in the home. | General population: More limited exposure assessment than described in “Good” category (e.g., 1-5 d); some details regarding measurement protocol provided.; Occupational settings: Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates); All settings: Uncertainty regarding correspondence between measured levels and levels in the etiologically relevant time window. For example, for studies of nighttime asthma symptoms, exposure measures taken at school or work. | General population: Short (<1 d) exposure measurement period; no or limited discussion of protocol - quality control assessment.; All settings: Large percentage (e.g., 50% or higher) of measures < LOD, or other ways in which exposure range does not allow analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.
Outcome (IB): | Incidence or prevalence of allergy symptoms - ISAAC questionnaires for rhinitis or rhinoconjunctivitis (in United States or Europe), or other validated questionnaire.; History of allergies – self-report of specific allergies. For children, skin prick tests covering at least 5 allergens.; Contact atopic dermatitis or eczema - validated questionnaire.; Current asthma (in past 12 mos or shorter time period) - ISAAC or other ATS-related questionnaires (in United States or Europe), or other validated questionnaire with similar level of sensitivity and specificity. | Prevalence of allergy symptoms - ISAAC or other questionnaire in areas other than US or Europe, without validation.; History of allergies - report of physician-diagnosed allergy (high specificity but low sensitivity). For adults - skin prick tests.; Atopic eczema. allergic rhinitis (in the past year) - self-report of medical treatment (medication use), without clarifying the type of medication.; Current asthma: ISAAC or other questionnaire in areas other than U.S. or Europe, without validation; self-report of medical treatment (medication use) for asthma in the past year. | History of allergies - self-report of allergies that includes food allergies.
Confounding (Cf) | Confounding considered and addressed in design or analysis. Primary potential confounders were age, gender, and respiratory exposures associated with the outcomes that were correlated with formaldehyde. | Confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with allergies or asthma may remain. | High likelihood of confounding that makes it unable to differentiate effect of formaldehyde from effect of other exposure(s).
Analysis and Other (Oth) | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. Data provided that allows characterization of the distribution of exposure, e.g., upper 75^th^ percentile. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.

Abbreviations: SB = selection bias; IB = information bias; Cf = confounding; Oth = other feature of design or analysis.

a These studies used in a separate evaluation of lower respiratory tract conditions in infants and children < 5 years.

#### Controlled Exposure Studies in Humans

The evaluation of controlled exposure studies examined four primary elements: the type of exposure (paraformaldehyde preferred over formalin or undefined test articles), use of randomization procedures to allocate exposure, blinding of the participant and of the assessor to exposure, and the details regarding the analysis and presentation of results (see Appendix B.3.4 for documentation of these study evaluations).

### 2.3.5 Respiratory Tract Pathology Study Evaluation Criteria

#### Studies in Humans

Considerations specific to the evaluation of the outcome assessment domain are described below; other evaluation domains pertaining to population (participant selection and comparability), exposure measurement, possibility of confounding, analysis and completeness of results, and study size, are discussed in Section 2.3.1. A table documenting the evaluation of each of the studies in this section is found in Appendix B.3.5.

For studies that evaluated histopathological lesions in nasal biopsies, EPA looked for either a detailed explanation of how tissues were evaluated and scored, or a citation for a standard method. Nasal biopsies were taken in four occupational studies; tissues were subsequently stained, and cell structure examined according to variations of the Torjussen et al. (1979) method. The original Torjussen method scored morphological characteristics of the nasal epithelium using a whole number between 0 and 8, with 0 indicating normal epithelium and 8 indicating carcinoma and the midpoint of four signifying stratified squamous epithelium with a horny layer. Despite the variations of this scale, in each study the lowest numbers (0 or 1) always indicated normal cell structure while increasingly higher numbers indicated more disruptive cellular changes. Although the focus of this section is nonneoplastic histopathologic lesions, the studies compared the means of the total score between exposed and referent groups. Therefore, the prevalence of dysplasia is presented in the evidence synthesis tables when it was reported.

The criteria relating to the evaluation of human respiratory tract pathology studies are outlined in Table 2-29.

Table 2-29 Criteria for domain ratings in epidemiology studies of respiratory pathology

Evaluation Domain | Primary criteria for domain ratings
Evaluation Domain | Good | Adequate | Deficient
Population (SB) | General population: Participant selection based on population-based sampling frame with high participation rate.; Occupational settings: High participation rate but potential for “healthy worker effect” to lead to attenuated effect estimate. | Uncertainty regarding participant recruitment process or participation rate. | General population: Participant selection based on exposure status.; Occupational settings: Recruitment process or self-selection likely to lead to inflated effect estimate.
Exposure (IB) | General population: Exposure measure based on at least 3-d sample; measures in more than one season if time window covers 12 months or addressed season in the analysis.; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure.; Relevant exposure period for nasal pathology is period prior to and during development of nasal lesions. | General population: More limited exposure assessment (e.g., < 1 d) with details regarding measurement protocol provided.; Occupational settings: Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates); All settings: Uncertainty regarding correspondence between measured levels and levels in the etiologically relevant time window. | All settings: Large percentage (e.g., 50% or higher) of measures < LOD, or other ways in which exposure range does not allow analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.; General population: Short (<1 d) exposure measurement period without discussion of protocol - quality control assessment.
Outcome (IB) | Cytopathology in nasal tissues: Detailed description of how tissues were evaluated and scored or citation to standard method.; Other endpoints: Detailed description or citation to standard method. | Nonstandard methods but documentation provided. | Nonstandard methods and no documentation establishing validity.
Confounding (Cf) | Confounding considered and addressed in design or analysis. Primary potential confounders were age, smoking, and respiratory exposures associated with the outcomes that were correlated with formaldehyde. | Confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with respiratory tract pathology may remain. | High likelihood of confounding that makes it unable to differentiate effect of formaldehyde from effect of other exposure(s),
Analysis and Other (Oth) | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. Data provided that allows characterization of the distribution of exposure, e.g., upper 75^th^ percentile. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.

#### Studies in Animals

In addition to the general factors considered for all toxicology studies of formaldehyde inhalation exposure (see Appendix B.3.1), factors specific to the interpretation of respiratory tract pathology were considered when determining study confidence. These criteria reflect the large database of well-conducted studies, and include: the use of too few test subjects (i.e., a sample size of less than 10 was considered a significant limitation); a failure to report lesion incidence and/or severity; the lumping of multiple lesions (e.g., squamous metaplasia and hyperplasia) together; a failure to report quantitative incidences and/or statistical analyses; the use of insensitive sampling procedures (multiple sections across multiple levels of the respiratory tract were preferred); and use of an exposure duration or follow-up that is likely insensitive for detecting slow-developing lesions (a duration of ≥1 year was preferred).

Somewhat in contrast to the available experimental animal studies for other health effect sections, most studies of respiratory pathology used paraformaldehyde or freshly prepared formalin as the test article, although some studies tested commercial formalin. As noted previously, while co-exposure to methanol is a major confounding factor for systemic endpoints, it is less of a concern (i.e., an adequate domain rating (“+”); see below) when identifying effects of inhaled formaldehyde on respiratory pathology. Most inhaled methanol bypasses the nose but is readily absorbed in the lungs and distributed systemically. Inhalation studies of methanol suggest that URT effects occur at concentrations many times higher than estimates of methanol concentrations in air, at least those generated from spraying formalin solutions onto heated glass^12^ (e.g., >650 mg/m^3^ in methanol studies by Poon et al. (1995) and Andrews et al. (1987) versus 5.5 mg/m^3^ methanol reported by Kamata et al. (1997) in a formalin study testing formaldehyde levels of 0 and 18.27 mg/m^3^). Thus, in general, the levels of methanol in formalin studies are considered unlikely to cause substantial increases in URT lesion severity. However, it does introduce the possibility that effective respiratory tract tissue concentrations of formaldehyde might be slightly higher after inhalation of formalin (due to some methanol conversion to formaldehyde within the tissue) than after exposure to the same concentrations of formaldehyde from sources without methanol, which would result in an overestimate of the effect of formaldehyde exposure and thus can influence study selection for dose-response analysis (see methods in Section 2.7).

For assessing histopathological changes for the different regions of rodent nasal passages, standard cross-section levels (e.g., Levels I−V) have generally been adopted for consistent analysis across studies (Young, 1981; Mery et al., 1994). Although the number and naming of cross-section levels varied from study to study, the levels always progressed through the nasal cavity from the area posterior to the nostrils (e.g., Level I or A) to areas anterior to the nasopharynx. Two different examples of the cross-sectioning procedures in rats are illustrated in Figure 2-2, with other studies of rats and other rodents employing similar procedures; however, illustrations of the specific cross-section levels used in each individual study are not included in the evidence tables.

Figure 2-2 Example cross-section levels in rat nasal passages used for histopathological evaluations from (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=2919565) Kerns et al. (1983) (left; Levels I-V) and Kamata et al. (1997) (right; Levels A-E)

For this assessment, it was preferred that studies assessed multiple tissue sections across multiple cross-section levels to allow for reasonable sampling of the nasal mucosa. Where applicable, histopathological findings in the nasal mucosa are discussed with reference to these sections, and the specific structures examined are stipulated in the evidence tables (e.g., nasoturbinates, maxilloturbinates, or ethmoid turbinates). When data were available, the type of epithelium affected (e.g., respiratory epithelium) was also noted. Only a few studies evaluated sections of the URT distal to the nasal cavity, and these evaluations were generally less rigorous (e.g., examining only a single tissue section) than evaluations of the nasal mucosa and tested much higher formaldehyde concentrations. Similarly, pathological findings in the LRT were generally not identified in studies with “good” or “adequate” exposure quality; thus, while these findings are briefly summarized in the evidence synthesis, separate criteria for outcome evaluation were not developed.

Table 2-30 describes the criteria used for the domain ratings informing the confidence classifications for animal studies of respiratory tract pathology.

Table 2-30 Criteria for domain ratings in animal studies of respiratory tract pathology

Evaluation domain | Overview of preferred study features | Primary criteria for domain ratings (Documentation shorthand used in Appendix B.3.5)
Evaluation domain | Overview of preferred study features | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Exposure Quality | Well-characterized and appropriate inhalation exposure conditions (See methods in Section 2.3.1, applied consistently across experimental studies; see documentation in Appendix B.3.1) | - “Good” Exposure Quality; [Note: for POE endpoints such as this, methanol co-exposure was not a major concern] | - “Adequate” Exposure Quality or “Deficient” Exposure Quality if the driver of the domain rating was use of formalin (i.e., this was not considered a critical deficiency for this POE effect) | - “Deficient” Exposure Quality not based on use of formalin as the test article; [Note: interpretation of the exposure levels is discussed in the hazard synthesis and is not, on its own, a reason for deficient]
Test Subjects | Sample size provides reasonable power to assess endpoint(s) in question; species, strain, sex, and age relevant to endpoint; no overt systemic toxicity noted or expected; allocations can be inferred as appropriate | - Based on OECD TG 452 and TG 413, chronic study: N ≥ 20; subchronic: N ≥ 10 (note: for this outcome, testing only one sex not a limitation); - Details on test subjects reported; - Randomization preferred (but not required) | - Small N (N= >3 to <10 in subchronic study; N= >3 to <20 in chronic study); - Individual less essential test subject details (e.g., sex) unclear | - Inadequate N (N ≤ 3); - Multiple less essential study details (e.g., sex, strain) unclear; - Individual essential study detail (e.g., species) unclear
Study Design | The design of the experiment is appropriate, reproducible, and sensitive for the endpoints of interest | - Study design, including exposure duration and timing of exposure and endpoint evaluation, are considered informative, discerning, and appropriate. | - Components of the study protocol were unclear or insufficiently assessed.; - Limited sensitivity of exposure timing or duration | - Study design could not be evaluated or had critical flaws (e.g., timing or duration or exposure likely to compromise the integrity of the findings)
Endpoint Evaluation | The protocols used to assess the outcome are sensitive, complete, discriminating (specific), and biologically sound (reliable); experimenter bias minimized | - Adequate use and reporting of discerning endpoint protocols, including blinding; - No potential confounding identified | - Limitation in conduct of evaluations (e.g., no lesion severity; limited sampling; lack of blinding); - Other uncontrolled variables unrelated to exposure quality may affect results | - Uncontrolled variables are expected to confound the results; - Lack of reporting lesion incidence and severity; - Multiple additive limitations
Data considerations and statistics | Statistical methods are presented, group comparisons and data/variability presentation are appropriate and discerning | - Adequate reporting and presentation of results; - No evidence of selective reporting; - Statistical methods described | - Failure to report statistical analyses; - Concern regarding selective reporting; - Concern with presentation of results (e.g., pooling of lesions) | - Failure to report enough data to interpret reported findings; - Multiple limitations

### 2.3.6 Study Evaluation Criteria for Mechanistic Information Related to Noncancer Respiratory Effects, Focusing on Inflammation and Immune Effects

#### Study Evaluations

Because many relevant articles (mostly experimental studies with multiple, relevant endpoints) were considered in this analysis, a method was developed to distinguish the experiments likely to provide the most useful information from those providing less informative data or a comparably negligible amount of information. Individual mechanistic studies were evaluated using basic screening-level criteria (see Table 2-31) for each relevant endpoint or group of related endpoints (e.g., hematological parameters) assessed by the study authors; thus, a study may be evaluated multiple times. Expert judgment of the totality of the potential limitations was used to determine a final level of confidence in the utility of the study results, with the reasoning documented. In some instances, notation is included regarding the sensitivity of the methods and whether they can provide information with direct relevance to interpreting cellular, structural, or functional changes related to potential respiratory system health effects. Although this information was not used in study evaluations, it was considered when developing the synthesis.

The study evaluation decision criteria were different for observational epidemiology studies and experimental studies, although all criteria emphasized exposure-related considerations. The intent of the criteria applied, and the purpose of this mechanistic evaluation, was to focus on potential mechanisms associated with constant, chronic inhalation exposure to formaldehyde. Some studies of other effects that might be related to respiratory health effects have been evaluated in other sections of the Appendix and support evaluations of potential respiratory hazards; these evaluations informed the interpretation of overlapping studies presented in this section, as well as in the MOA analyses presented in the toxicological review. Studies of cellular proliferation, mucociliary function, and genotoxicity were separately reviewed, with the relevant conclusions directly incorporated into the MOA analyses described in the Toxicological Review. The application of the decision criteria to the identified mechanistic studies is presented in Appendix B.3.6. Interpretations of the usefulness of the individual mechanistic studies for evaluating the effect(s) in question were drawn based on the results of applying the decision criteria. Specifically, regarding the mechanistic studies related to potential noncancer respiratory effects (focusing on immune and inflammatory changes), given the large number of studies identified, individual experiments were characterized as high or medium confidence, low confidence, or not informative. These evaluations emphasized exposure-related considerations and were designed to identify the mechanistic data most likely to be associated with constant, chronic inhalation exposure to formaldehyde (see Appendix B.3.6 for additional details). These interpretations were high or medium confidence—experiments considered very useful for describing potential formaldehyde inhalation-induced effects (since both medium and high confidence studies were considered well conducted, additional criteria were not applied to distinguish one from the other). In contrast, low confidence experiments might provide useful information, but should be considered in the context of other available data. Not informative studies were interpreted as providing negligible information regarding the potential for formaldehyde inhalation to cause the effect(s) of interest and were ultimately not included in the mechanistic analyses, given the identified limitations and the large number of available studies. Note that studies evaluating tissues interpreted as unlikely to be contributing to respiratory health effects (e.g., liver) are included in Appendix B.3.6, but are not included in the MOA analyses presented in the Toxicological Review or the systematic evidence map; the relative importance and ultimate decision to not include such information in the mechanistic analyses may change if the conclusion regarding their lack of relevance to respiratory health effects were to change with additional, future research.

Table 2-31 describes the criteria used for the domain ratings informing the confidence classifications for mechanistic studies relevant to potential noncancer respiratory effects.

Table 2-31 Decision considerations for the evaluation of mechanistic studies relevant to potential noncancer respiratory effects

Observational studies preferences | Experimental studies (human or animal, controlled exposure) preferences
Generally, studies were considered low confidence if they had multiple (2 or more) unmet preferences and not informative if the majority of preferences were not met: | Generally, studies were considered low confidence if they had multiple (2 or more) unmet preferences and not informative if the majority of preferences were not met:
Exposure duration; - duration ≥5 d (acute exposures noted); - daily exposures of several hours | System; - in vivo with nose-only or whole-body inhalation exposure
Exposure levels; - inhaled concentration accurately quantified in exposed group; - use of an appropriate referent group; - exposure contrast expected to allow for detection of differences across groups | Test article; - explicit use of paraformaldehyde (PFA) or methanol-free preparations of formaldehyde; note: experiments of non-URT tissues/models (including lung) were automatically “low confidence” if this preference was not met)
Comparability; - endpoint result comparisons can discern effects of formaldehyde exposure alone (e.g., controlling for co-exposures, blinding) | Exposure paradigm; - duration of ≥5 d (acute exposures noted); - periodicity of ≥5 hrs/d and ≥5 d/week (if ≥1 d)
Sample size; - >10 persons/ group to (theoretically) reduce variability | Exposure levels; - inhaled concentration was quantified (as ppm, mg/L or mg/m^3^); - at least one tested exposure level of ≤3 mg/m^3^; (Note: studies only testing above 10 mg/m were considered “excessive”)
Reporting; - clear description of methods; - detailed, quantitative reporting of results | Comparability; - endpoint result comparisons can discern effects of formaldehyde exposure alone (e.g., controlling for other experimental manipulations, including chamber air exposure).
Reporting; - clear description of methods; - detailed, quantitative reporting of results | Sample size; - >10 humans or >5 animals/ group to (theoretically) reduce variability
Reporting; - clear description of methods; - detailed, quantitative reporting of results | Reporting; - clear description of methods; - detailed, quantitative reporting of results

#### Specific Evaluation and Summary of URT mucociliary function and cellular proliferation

Studies examining the potential effects of formaldehyde exposure on mucociliary function and cell proliferation were considered for use in identifying potential hazards associated with respiratory tract pathology effects but were ultimately determined to be most useful as mechanistic evidence describing the potential progression of effects on structures within the URT that might lead to more apical effects (e.g., squamous metaplasia). In contrast to the other mechanistic studies described in this section, these observational human studies and experimental animal studies were individually evaluated according to the criteria laid out for human and animal apical endpoint (i.e., hazard) studies described in Appendix B.3.6, noting that the decisions for the specific endpoints considered in this section can differ when interpretations of the reliability of the methods differed from those of the more apical endpoints. Thus, studies were judged as high, medium, or low confidence, or as “not informative” (i.e., not discussed).

### 2.3.7 Nervous System Effects Study Evaluation Criteria

The literature searches (see Section 2.2.7) identified observational epidemiology studies of neurobehavioral effects and of risk of amyotrophic lateral sclerosis (ALS), controlled human exposure studies of neurobehavioral effects, and experimental animal inhalation exposure studies examining a variety of endpoints (e.g., learning and memory; motor activity, habituation, and anxiety; neuropathology). The specific criteria for evaluation are described below.

#### Human Observational Epidemiology Studies

Amyotrophic lateral sclerosis is a rare neurodegenerative disorder of the motor neurons with an incidence in Western countries of 1–2 per 100,000 person-years (Ingre et al., 2015). Three of the studies of ALS evaluated ALS mortality; analysis of mortality rather than incidence was not considered to be a limitation. Because the 5-year survival rate is low, mortality studies of ALS provide a good estimate for incidence of this disease. Because the disease is rare, the precision of risk estimates reported by these studies is a major limitation; for most of the studies, the number of exposed cases for the case-control studies or total cases ascertained for the cohort studies was small. Established risk factors that should be considered as potential confounders are age, and sex. Smoking also has been associated with ALS in multiple studies. Family history is also a risk factor but would not likely be associated with formaldehyde exposure; therefore, controlling for family history was not considered essential. While potential misclassification of exposure was another limitation for all of the studies, this was a particular concern for the general population studies, which collected exposure information using questionnaires (Weisskopf et al., 2009; Fang et al., 2009) or job-exposure matrices based on industry or occupation (Seals et al., 2017; Roberts et al., 2015; Peters et al., 2017). Fang et al. (2009) used a more detailed evaluation of exposure level and duration based on a structured occupational questionnaire and classification by industrial hygienists. Peters et al. (2017) and Seals et al. (2017) assigned individuals to exposure categories using the Nordic Occupational Cancer Study job exposure matrix which contained formaldehyde concentration data specific to either Sweden or Denmark; data on occupations over time were obtained from national censuses in Sweden (Peters et al., 2017) or the National Pension Fund in Demark (Seals et al., 2017). Roberts et al. (2015) used data from the National Longitudinal Study in the United States, which obtained information via a survey on the most recent occupation at the time subjects were enrolled; information on later occupations during follow-up was not captured.

Table 2-32 describes the criteria used for the domain ratings informing the confidence classifications for epidemiology studies of nervous system effects.

Table 2-32 Criteria for rating domains in epidemiology studies of nervous system effects

Evaluation domain | Primary criteria for domain ratings
Evaluation domain | Good | Adequate | Deficient
Population (SB) | General population: Participant selection based on population-based sampling frame with high participation rate.; Case-control: Selection from same source population; Occupational settings: Cohort studies uncompromised by loss-to-follow up. | Uncertainty regarding participant recruitment process or participation rate. | General population: Participant selection based on exposure status.; Occupational settings: Recruitment process or self-selection likely to lead to inflated effect estimate.
Exposure (IB) | ALS Case-Control (occupational settings): Long-term and short-term job history with industry, occupation and task details allowing for independent assessment of exposure potential. Use of a validated job-exposure matrix (JEM).; ALS Cohort studies: Long-term and short-term job history with industry, occupation and task details allowing for independent assessment of exposure potential supported by formaldehyde monitoring data.; Etiologically relevant time window (ALS): Previous 20 years prior to diagnosis and design that excludes prevalent cases.; Neurobehavior (occupational settings): Ability to differentiate between exposed and unexposed, or between low and high exposure. Exposure assessment specific to formaldehyde exposures and using some concentration measurements; includes assessment of intensity and frequency (for example, job exposure matrix).; Relevant time window (neurobehavior): Period prior to health assessment | Cohort studies: Job history with industry and occupation, although task-level details not available, and job histories may not be complete. Use of a validated JEM.; ALS Case-Control (occupational settings): Job history with industry and occupation, although task-level details not available, and job histories may not be complete. Use of a validated JEM.; Neurobehavior (occupational settings): Ability to differentiate between exposed and unexposed, or between low and high exposure but greater possibility of misclassification (e.g., exposure definition not informed by measurements or job exposure matrix not validated for population). Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates) | General population: Short (<1 d) exposure measurement period without discussion of protocol - quality control assessment.; ALS Case-Control (occupational settings): Exposure definition includes group with large variation in probability or intensity of exposure with likely attenuation of results; Exposure definition based only on industry/occupation codes or other exposure ascertainment with potential to include high numbers of nonexposed or inadequate sensitivity (e.g. “ever-never exposed; use of open-ended question regarding occupational exposures.; Neurobehavior (all settings): Large percentage (e.g. 50% or higher) of measures < LOD, or other ways in which exposure range does not allow analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.
Outcome (IB) | ALS: Incidence or mortality; ICD-7 356.1, ICD-8 348.0, ICD-9 335.2, ICD-10 G12.2. Source of cases from national registries or hospital-based diagnoses by specialists in motor neuron disease. Deaths from death certificates or National Death Index.; Neurobehavior: Standardized neurobehavioral test battery administered by trained technician. | ALS: Outcome ascertainment same as for high.; Neurobehavior: Incomplete test battery | Neurobehavior: Instrument or methods for data collection not described. Symptoms reported with knowledge of exposure status.
Confounding (Cf) | Confounding considered and addressed in design or analysis. Primary potential confounders for ALS were age, gender, smoking, and respiratory exposures associated with the outcomes that were correlated with formaldehyde. Primary potential confounders for neurobehavior outcomes were age, gender and education. | Confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with ALS or neurobehavior may remain. | High likelihood of confounding that makes it unable to differentiate effect of formaldehyde from effect of other exposure(s),
Analysis and Other | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.

#### Controlled Exposure Studies in Humans

Controlled exposure studies in humans were evaluated as described for sensory irritation endpoints in Section 2.3.2. In addition to the general considerations for study evaluation, the controlled human exposure studies that assessed a battery of neurobehavioral tests were evaluated with respect to the completeness and appropriateness of the battery of tests used, and the timing of their administration with respect to exposure as noted for epidemiology studies except they included consideration of the potential for irritant responses to influence behaviors due to concurrent or near-concurrent exposures, as discussed for animal studies below.

#### Studies in Animals

Evaluations of animal studies of nervous system effects only encompass studies reporting results following in vivo inhalation exposures. Noninhalation exposures are expected to involve significant distribution of formaldehyde beyond the portal of entry (which is not observed to an appreciable extent following inhalation exposure), and thus were not considered to be informative to the evidence synthesis. In vitro studies were similarly excluded from this analysis.

In addition to the general criteria discussed in Section 2.3.1, considerations specific to the evaluation of potential nervous system effects were also evaluated. Due to the known neurotoxicity hazard of methanol, studies failing to use an appropriate test article were automatically assigned low confidence and, to avoid confusion with methanol’s effects, if they evaluated high exposure levels (defined here as relying only on exposures > 10 mg/m^3^) they were deemed to be not informative. Additional criteria included: consideration of the potential influence of irritation or changes in olfaction on behavioral measures (e.g., exposure during behavioral training was considered a limitation; a preference was given to behavioral studies with a period of latency between exposure and endpoint testing of 24 hours, or 2 hours at a minimum); blinding of the outcome assessors was preferred for subjective measures (e.g., slide evaluation; behavioral observations; etc.), although this was not necessarily considered a limitation for automated measures; a sample size of n = 10/group was preferred; methods include a description of and a preference for endpoint evaluation procedures that are sensitive and specific for the detection of potential nervous system effects (see Table 2-33 for additional details). Although studies with a longer exposure duration were most relevant to interpreting the lifetime neurotoxicity hazard of inhaled formaldehyde, nervous system effects studies of short term or even acute duration were not automatically considered to be less informative (i.e., exposure duration < 28 days was indicated as a minor limitation). This is somewhat in contrast to the interpretation of animal studies in other sections (e.g., respiratory tract pathology), and this reflects an understanding that neurotoxic effects from very brief exposures can oftentimes represent important health concerns.

Table 2-33 describes the criteria used for the domain ratings informing the confidence classifications for animal studies of nervous system effects.

Table 2-33 Criteria for domain ratings in animal studies of nervous system effects

Evaluation domain | Overview of preferred study features | Primary criteria for domain ratings (Documentation shorthand used in Appendix B.3.7)
Evaluation domain | Overview of preferred study features | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Exposure quality | Well-characterized and appropriate inhalation exposure conditions (See methods in Section 2.3.1, documentation in Appendix B.3.1) | - “Good” Exposure Quality; [Note: for non-POE endpoints such as this, methanol co-exposure is a major concern] | - “Adequate” Exposure Quality | - “Deficient” Exposure Quality; [Note: interpretation of the tested exposure levels is discussed in the hazard synthesis]
Test subjects | The species, sex, strain, and age are appropriate for the endpoint(s); sample size provides reasonable power to assess the endpoint(s); overt systemic toxicity is absent or not expected, or it is accounted for; group allocations can be inferred as appropriate | - Details on test subjects reported; - No toxicity observed or expected; - Randomization preferred (but not required); - N ≥ 10 | - Small N (e.g., N= >3 to <10); - Individual less essential test subject details (e.g., sex) unclear; - Examination of only one sex | - Inadequate N ≤ 3; - Multiple less essential study details (e.g., sex, strain) unclear; - Individual essential study detail (e.g., species) unclear; - Allocations viewed as inappropriate; - Overt systemic toxicity
Study design | A study focus was nervous system effects; the exposure regimen is informative for the tested endpoint; latency from exposure to testing reduces the potential for irritation-driven responses; [underlined: Note:] No guideline or GLP studies were identified | - Study design, including exposure duration and timing of exposure and endpoint evaluation, are considered informative, discerning, and appropriate. | - Limited sensitivity of exposure timing or duration; - Unclear if potential confounding variables were introduced | - Behaviors tested during or shortly after exposure (irritant effects likely); - Lack of control for litter effects in developmental study designs; - Other confounding likely due to design
Endpoint evaluation | The protocols used to assess the nervous system effects are sensitive for detecting an effect, complete, discriminating (i.e., specific for the response in question), and biologically sound; experimenter and sampling bias minimized | - Adequate use and reporting of discerning endpoint protocols, including blinding | - Limited evaluations; - Incomplete reporting of methods | - Lack of essential blinding; - Only cursory observations; - Multiple additive limitations; - Critical methodological details missing
Data considerations and statistics | Statistical methods are reported, group comparisons and data presentation (including variability) are complete, appropriate, and discerning; selective reporting bias avoided | - Adequate reporting and presentation of results; - No evidence of selective reporting; - Statistical methods described | - Failure to report statistical analyses; - Concern regarding selective reporting; - Concern with presentation of results (e.g., no reporting of motor activity in learning and memory tests) | - Failure to report a sufficient amount of data to interpret reported findings; - Multiple limitations

#### Studies Specific to Mechanistic Considerations Only

In vivo inhalation studies examining mechanistic events related to nervous system effects were systematically evaluated to inform biological plausibility. Although parallel criteria to those used to evaluate studies describing potential neurotoxicity health effects (see above) were used to judge the mechanistic studies, the stringency of some criteria were adapted to accommodate this type of information and additional leniency was applied for certain parameters (e.g., acute exposure was not considered a limitation).

### 2.3.8 Developmental and Reproductive Toxicity Study Evaluation Criteria

The literature searches (see Section 2.2.8) identified observational epidemiology and experimental animal studies relevant to developmental and reproductive toxicity. The specific criteria for evaluation are described below, with the documentation of the application of these criteria to individual studies provided in Appendix B.3.8.

#### Human Studies

##### Participant Selection

A key consideration with respect to occupational studies of spontaneous abortion or time to pregnancy is the potential for selection bias if participants are recruited from current employees (Axelsson, 1984) (Slama et al., 2014; Baird et al., 1986). Another potential bias may result from which pregnancy (first, pregnancy during defined time period, most recent) is selected as the index pregnancy in studies of spontaneous abortion. Studies that focus on the most recent pregnancy may be less sensitive due to time-lapse bias. The time between a pregnancy ending in spontaneous abortion and a subsequent pregnancy ending in a live birth is often shorter than two pregnancies, both ending in live births. This can result in a bias toward identifying live births as the most recent pregnancy (Wilcox, 2010).

##### Outcome ascertainment

The validity of retrospectively collected self-completed questionnaire data on time-to-pregnancy (TTP) closely reproduced the distributions of TTP in the group using a different data source (e.g., data collected during annual follow-up of a family planning cohort), even over recall durations greater than 14 years (Joffe et al., 1995). In addition, subfertility, defined as a TTP greater than 12 months using the questionnaire data, was identified with high sensitivity (79.9%) and specificity (94.9%) (Joffe et al., 1993). However, individuals recalled the number of months before conception with greater error, and these errors increased as the duration of time-to-pregnancy increased. Longer TTP was both over- and under-estimated (Joffe et al., 1995; Cooney et al., 2009). Therefore, while individual estimates of TTP may be less precise, the comparison of group means with respect to levels of formaldehyde exposure is likely to be informative. Validity studies indicate that recall of previous spontaneous abortions is relatively complete, particularly for losses that occurred after the 8th week of gestation (> 80% of recorded spontaneous abortions were recalled) (Wilcox and Horney, 1984). Completeness varies by occupation; completeness of recall among nurses was better than that among industrial workers (Lindbohm and Hemminki, 1988; Axelsson and Rylander, 1982). Although elapsed time since the event occurred may also influence the completeness of recall, this also varied by occupation in a similar way (not important among nurses) and was not important within the first 10 years after the event (Wilcox and Horney, 1984; Lindbohm and Hemminki, 1988). It is difficult to evaluate the validity of self-reports of spontaneous abortion occurring during the 1st trimester using medical records because these early events often are not recognized or do not require medical intervention; medical records may not necessarily be an accurate reference (Slama et al., 2014; Lindbohm and Hemminki, 1988).

The criteria that were used for the domain ratings informing the confidence classifications for epidemiology studies of reproductive and developmental effects are included in Table 2-34.

Table 2-34 Criteria for domain ratings in epidemiology studies of reproductive and developmental effects

Evaluation domain | Primary criteria for domain ratings
Evaluation domain | Good | Adequate | Deficient
Population (SB) | General population; For time-to-pregnancy: Birth cohort participants enrolled prior to or within first weeks of pregnancy. High participation rate.; For birth outcomes: Birth cohort participants enrolled within first weeks of pregnancy. High participation rate.; Occupational settings; For time-to-pregnancy: Recruitment from registries, occupational payroll, or union records. High participation rate.; For spontaneous abortion or birth outcomes: Cases and controls selected from same source. Controls selected from working population or during periods of employment. Case definition was first pregnancy or all pregnancies occurring during study period. | General population; For time-to-pregnancy: Birth cohort participants enrolled after 1^st^ trimester of pregnancy; hospital-based cohort.; Occupational settings; Case definition was most recent pregnancy (decreased sensitivity); All settings: Uncertainty regarding participant recruitment process or participation rate. | General population: Participant selection based on exposure status.; Occupational settings: Recruitment process or self-selection likely to lead to inflated effect estimate.
Exposure (IB) | General population: Exposure measure based on at least 3-d sample; measures in more than one season if time window covers 12 mos or addressed season in the analysis.; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure. Exposure assessment specific to formaldehyde exposures and using some concentration measurements; includes assessment of intensity and frequency (for example, job exposure matrix).; Etiologically relevant time window (all settings):; Time to pregnancy: Period prior to or during pregnancy attempt.; Spontaneous abortion: Preconception and during 1^st^ trimester.; Period of spermatogenesis (paternal exposure); Other birth outcomes: Exposure during pregnancy. | General population: More limited exposure assessment (e.g., < 1 d) with details regarding measurement protocol provided.; Occupational settings: Ability to differentiate between exposed and unexposed, or between low and high exposure but greater possibility of misclassification (for example, exposure definition not informed by measurements or job exposure matrix not validated for population). Referent group may be exposed to formaldehyde or to other exposures affecting respiratory conditions (potentially leading to attenuated risk estimates); All settings: Uncertainty regarding correspondence between measured levels and levels in the etiologically relevant time window. | General population: More limited exposure assessment (e.g., < 1 d) and no details regarding measurement protocol provided.; Occupational settings: Exposure definition includes group with large variation in probability or intensity of exposure with likely attenuation of results; Exposure definition based only on industry/occupation codes or other exposure ascertainment with potential to include high numbers of nonexposed or inadequate sensitivity (e.g., use of open-ended question regarding occupational exposures.); All settings: Large proportion (>50%) less than the LOD for analyses of continuous exposures or other ways in which exposure range does not allow analysis of risks above 0.010 mg/m^3^; small exposure contrast between exposure groups limits ability to detect differences.
Outcome (IB): | Time-to-pregnancy: Based on interview/questionnaire among birth cohort during study period.; Spontaneous abortion: Self-report with or without verification using hospital records.; Birth outcomes: Gestational age, birth weight, birth length, head circumference obtained from birth records. Other methods with high sensitivity and specificity validated in target population. Birth defects reported in registry. | Time-to-pregnancy: Recall based on interview/questionnaire.; Spontaneous abortion: Hospital discharge records. Exclusion criteria potentially resulted in missing events (for example, pregnancies identified from birth register).; Birth outcomes: Gestational age, birth weight, birth length, head circumference obtained from birth records. Other methods with high sensitivity and specificity, but not validated in target population. | All endpoints: No information about source of or methods for outcome ascertainment.
Confounding (Cf) | Confounding considered and addressed in design or analysis. Primary potential confounders were maternal age, smoking, and exposures associated with TTP or spontaneous abortion that were correlated with formaldehyde. | Confounding considered and addressed in design or analysis but some questions regarding degree of correlation between formaldehyde and other exposures associated with TTP or spontaneous abortion may remain. Adjustment for pregnancy history is considered to be a limitation. | High likelihood of confounding that makes it unable to differentiate effect of formaldehyde from effect of other exposure(s).
Analysis and Other (Oth) | Analysis allows for examination of variation in effect in relation to variation in exposure level using analytic procedures that are suitable for the type of data. | Sample size limited in stratified analyses. | Limited data analysis (or analysis that is not appropriate for the data) or small overall sample size increased potential for unreliable results.

#### Animal Studies

Only in vivo inhalation exposure studies are used for hazard identification and dose-response assessment. These studies were conducted in inhalation chambers under controlled experimental conditions. Studies that exposed animals to formaldehyde via other routes or in vitro were not included because they are expected to result in significant distribution of formaldehyde past the portal of entry, which does not occur to an appreciable extent with inhalation exposures.

A key consideration for the interpretation of developmental and reproductive outcomes associated with inhalation exposures to formaldehyde in experimental studies was the potential for co-exposure to methanol, a known developmental and reproductive toxicant (U.S. EPA, 2013), when the test article was an aqueous solution of formaldehyde. Such studies were automatically assigned a low confidence classification (or not informative if additional study limitations were identified) and contributed little to the synthesis of evidence regarding formaldehyde effects on development or the reproductive system.

In addition to the general criteria discussed in Section 2.3.1, considerations specific to the evaluation of potential developmental or reproductive system effects are described in Table 2-35.

Table 2-35 Criteria for domain ratings in animal studies of developmental and reproductive effects

Evaluation domain | Overview of preferred study features | Primary criteria for domain ratings (Documentation shorthand used in Appendix B.3.7)
Evaluation domain | Overview of preferred study features | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Exposure Quality | Well-characterized and appropriate inhalation exposure conditions (See methods in Section 2.3.1, documentation in Appendix B.3.1) | - “Good” Exposure Quality; [Note: for non-POE endpoints such as this, methanol co-exposure is a major concern] | - “Adequate” Exposure Quality | - “Deficient” Exposure Quality; [Note: interpretation of the tested exposure levels is discussed in the hazard synthesis]
Test Subjects | Sample size provides reasonable power to assess endpoint(s) in question; species, strain, sex, and age are appropriate for the endpoint; overt systemic toxicity not noted or expected; group allocations can be inferred as appropriate | - Details on test subjects reported and appropriate; - No toxicity observed or expected; - Randomization preferred (but not required); - N ≥ 10 (preferably at least 20 dams/group, consistent with standard guideline developmental and reproductive toxicity studies) | - Small N (e.g., N= >3 to <10); - Individual less essential test subject details (e.g., sex) unclear; - Examination of only one sex; - Potential concern for species, strain, or lifestage-related differences in reproductive schedules and outcome sensitivity; - Study did not clearly evaluate toxicity (e.g., maternal) or it is a potential concern | - Inadequate N ≤ 3; - Multiple less essential study details (e.g., sex, strain) unclear; - Individual essential study detail (e.g., species) unclear; - Allocations viewed as inappropriate; - Evidence for a major concern with test subject insensitivity; - Overt systemic toxicity expected to be a driver of effects
Study Design | A study focus was developmental or reproductive system effects; the exposure regimen is informative for the tested endpoint(s); manipulations other than formaldehyde exposure are adequately controlled | - Study design, including exposure duration and timing of exposure and endpoint evaluation, are considered informative, discerning, and appropriate. | - Components of the study design were unclear or insufficient.; - Limited sensitivity of exposure timing or duration; - Design of study is limited, not examining a wide range of potential effects | - Study design could not be evaluated or had critical flaws (e.g., timing or duration or exposure likely to compromise the integrity of the findings)
Endpoint Evaluation | The protocols used to assess the endpoint(s) are sensitive, complete, discriminating (specific), and biologically sound (reliable); experimenter bias minimized | - Adequate use and reporting of discerning endpoint protocols, including blinding; - No potential confounding identified | - Limitation in conduct of evaluations (e.g., limited sampling; lack of blinding); - Other uncontrolled variables unrelated to exposure quality may affect results | - Uncontrolled variables are expected to confound the results; - Multiple additive limitations
Data considerations and statistics | Statistical methods are reported, group comparisons and data/variability presentation are appropriate and discerning; selective reporting bias avoided | - Adequate reporting and presentation of results; - No evidence of selective reporting; - Statistical methods described; - For developmental studies, litter was the primary unit of analysis | - Failure to report statistical analyses; - Concern regarding selective reporting; - Concern with presentation of results (e.g., pooling of lesions) | - Failure to report a sufficient amount of data to interpret reported findings; - Multiple limitations; - Significant concern for litter bias

### 2.3.9 Carcinogenicity Study Evaluation Criteria

The literature searches (see Section 2.2.9) identified observational epidemiology and experimental animal studies relevant to cancer. The specific criteria for evaluation are described below, with the documentation of the application of these criteria to individual studies provided in Appendix B.3.9.

#### Cancer Studies in Humans

The focus of EPA’s examination is on several specific types of upper respiratory tract (URT) and lymphohematopoietic (LHP) cancer. The evaluation of LHP cancers includes four different subtypes: myeloid leukemia (including monocytic leukemia), lymphatic leukemia, multiple myeloma, and Hodgkin lymphoma. Among upper respiratory cancers, four different types are reviewed: sinonasal (SNC), nasopharyngeal cancer (NPC), oro/hypopharyngeal cancer (OHPC), and laryngeal cancer.

##### Evaluation of Observational Epidemiology Studies of Cancer

The epidemiology studies examined occupational exposure to formaldehyde either in specific work settings (e.g., cohort studies) or in case-control studies. The considerations with respect to design, exposure assessment, outcome assessment, confounding and analysis differ for these different types of studies and are discussed in more detail below.

Each study identified by the literature search as potentially relevant to inform the causal evaluation of whether formaldehyde exposure causes cancer was evaluated and classified for the study’s ability to inform a hazard conclusion for a particular cancer outcome. Study evaluation encompasses interpretations regarding a variety of methodological features (e.g., study design, exposure measurement details, study execution, data analysis). Developing an outcome-specific study evaluation for each cancer outcome encompasses two concepts: minimization or control of bias (internal validity), and sensitivity/appropriateness (the ability of the study to detect a true effect). The purpose of this step is not to eliminate studies, but rather to evaluate studies with respect to potential methodological considerations that could affect the interpretation of or confidence in the results.

1) Consideration of participant selection and comparability

- Whether there is evidence of selection into or out of the study (or analysis sample) that was jointly related to exposure and to outcome.
  - For cohort studies, EPA considered the extent of follow-up, and the likelihood that completeness of follow-up was related to exposure level. Most of the cohort studies examining mortality data reported high rates of follow-up with respect to ascertainment of vital status and ascertainment of cause of death (90–95% or higher); in some cases, the latter figure (i.e., percentage of decedents with death certificates) was not provided by the study authors. Two studies were able to obtain only 79% (Hayes et al., 1990) or 75% (Walrath and Fraumeni, 1984) of the identified death certificates but as both studies were of embalmers who were all considered to have been exposed to formaldehyde, the absence of data (missingness) was considered to have been random.
  - For case-control studies, controls are optimally selected to represent the population from which the cases were drawn (e.g., similar geographic area, socioeconomic status, and time period). A variety of methods were used in the identified studies, including random digit dialing and use of population registries. The interest and motivation to participate is generally higher for cases than for controls, particularly in population-based settings. A low participation rate of either or both groups does not in itself indicate the occurrence of selection bias; a biased risk estimate is produced if exposure and disease are jointly related to participation rates, but not if either is independent of participation rates. For example, a bias is not necessarily produced if cases are more likely to participate than controls; a bias can be produced, however, if cases with high exposure are more likely to participate than cases with low exposure. Most of the case-control studies were conducted using incident (or recently diagnosed) cases, with participation rates ranging from approximately 75% to 99%. Participation among population-based controls generally ranged from 75% to 85%, with higher rates seen in some studies using hospital-based designs. Differences in participation rates between case and controls potentially related to exposure were considered more prone to bias (Beane Freeman et al., 2013). Certain studies used cases’ next of kin to ascertain the cases’ occupational history from which the individual’s exposure to formaldehyde was derived. The difference in methods for recruiting cases and controls creates a potential for selection bias and a potential for information bias when the accuracy of exposure histories differs between deceased cases and the controls (e.g., (Yang et al., 2005; Vaughan et al., 1986a, b; Vaughan, 1989)).
- An uncommon issue related to potential selection bias was the “healthy worker effect” in cohort studies where a working population is compared to that of the general public—a bias which can result in underestimates of any adverse effect of exposure. While this phenomenon is generally considered to be a stronger influence in evaluation of cardiovascular health endpoints, there is evidence that there can be a strong healthy worker effect in studies of cancer endpoints (Sont et al., 2001). In cohort studies, the potential for selection bias due to the healthy worker effect was assessed by examination of the all-cause cancer effect estimates; studies with estimates <90% of expected were judged to be potentially biased towards lower overall cancer occurrence and lower levels of cases detection resulting in underestimates of any true effect. Severe underestimates of <80% of expected cases were noted as well (e.g., (Wesseling et al., 1996; Stroup et al., 1986; Robinson et al., 1987; Matanoski, 1989; Levine et al., 1984b; Harrington and Oakes, 1984; Hall et al., 1991)).
- For some cancers, the reliance of cohort studies on death certificates to detect cancers with relatively high survival may have underestimated the actual incidence of those cancers, especially when the follow-up time may have been insufficient to capture all cancers that may have been related to exposure. The potential for bias may depend upon the specific survival rates for each cancer. Five-year survival rates vary among the selected cancers (Table 2-36), from 86% for Hodgkin lymphoma (HL) to less than 50% for multiple myeloma (MM), myeloid leukemia (ML), and oro/hypopharyngeal cancer. EPA considered the likelihood of underreporting of incident cases to be higher for mortality-based studies of HL and LL which may result in undercounting of incident cases and underestimates of effect estimates compared to general populations (e.g., (Solet et al., 1989; Mayr et al., 2010; Hayes et al., 1990; Hansen et al., 1994; Hansen and Olsen, 1995)).

Table 2-36 Lymphohematopoietic and upper respiratory cancers: age-Adjusted SEER incidence and U.S. death rates and 5-year relative survival by primary cancer site^a^

Cancer site | Incidence rate (per 100,000); 2008–2012 | Expected cases^b^; 2014 | Mortality rate (per 100,000)^c^; 2008–2012 | Expected deaths^d^; 2014 | 5-Year survival (%); 2005–2011
Lymphohematopoietic Cancers
Hodgkin lymphoma (HL) | 2.7 | 8,336 | 0.4 | 1,235 | 85.9
Multiple myeloma (MM) | 6.3 | 19,451 | 3.3 | 10,189 | 46.6
Lymphatic Leukemia (LL) | 6.6 | 20,377 | 1.9 | 5,866 | 77.6
Acute lymphatic leukemia (ALL) | 1.7 | 5,249 | 0.4 | 1,235 | 67.5
Chronic lymphatic leukemia (CLL) | 4.5 | 13,894 | 1.4 | 4,322 | 81.7
Other | 0.4 | 1,235 | 0.1 | 309 | 80.6
Myeloid & monocytic leukemia (ML) | 6.1 | 18,833 | 3.4 | 10,497 | 37.5
Acute myeloid leukemia (AML) | 4.0 | 12,350 | 2.8 | 8,645 | 25.9
Chronic myeloid leukemia (CML) | 1.7 | 5,249 | 0.3 | 926 | 63.2
Acute monocytic | 0.2 | 617 | 0.0 | 0 | 23.5
Other | 0.2 | 617 | 0.2 | 617 | 33.2
Upper Respiratory Tract Cancers
Nose, nasal, & middle ear^e^ | 0.7 | 2,161 | 0.1 | 309 | 55.3
Nasopharynx | 0.6 | 1,852 | 0.2 | 617 | 59.6
Oropharynx | 0.4 | 1,235 | 0.2 | 617 | 41.7
Hypopharynx | 0.6 | 1,852 | 0.1 | 309 | 32.2
Larynx | 3.2 | 9,880 | 1.1 | 3,396 | 60.6

a Incidence rates and 5-year survival from Surveillance, Epidemiology, and End Results (SEER), 18 areas. Results. [http://seer.cancer.gov/csr/1975_2012/results_merged/topic_survival.pdf], last accessed August 14, 2015.

b EPA calculated the expected number of cases based on incidence rates applied to U.S. census population estimate for 2014 of 308,745,538 (http://www.census.gov/search-results.html?q=2014+population&page=1&stateGeo=none&searchtype=web).

c U.S. Mortality Files, National Center for Health Statistics, Centers for Disease Control and Prevention

d SEER 18 areas. Based on follow-up of patients into 2012.

e SEER does not publish specific data on sinonasal cancer which would be included in the published category labeled “Nose, nasal & middle ear.”

2) The reliance of case-control studies on prevalent cases rather than incident cases.

In order to accrue a sufficiently large population of rare cancer cases, some studies may include cases which have been detected over a long period of time and thus include many prevalent cases at the time of analysis. Restriction to only living cases may lead to over-representation of cancer survivors or, if next of kin are used to provide proxy information on cases, the quality of that data may then differ between cases and controls which can be a concern if differences may be related to exposure. Hence, EPA considers that there is some risk of selection bias in studies examining prevalent cases (Yang et al., 2005; Vaughan et al., 1986a, b; Vaughan, 1989; Pesch et al., 2008; Mayr et al., 2010; Armstrong et al., 2000).

3) Evaluation of exposure assessment

At a minimum, exposure to formaldehyde may be inferred based on the specific occupations (e.g., carpenter, embalmer, pathologist) or industry (e.g., production or use of formaldehyde resins, wood-products, paper, textiles, foundries). Independent testing of various workplaces may provide approximate exposure measurements and ranges for inferred exposures. Details in each study may reveal the extent of exposure within occupational groups or at the individual-level based on job histories. Some studies may have documented formaldehyde exposures using exposure monitors or quantified the absolute or relative exposure for different tasks, which may be matched to individual occupational patterns using” job exposure matrices” or JEMs. The quality of the exposure measure is evaluated with respect to the accuracy of the measures and their related potential for exposure measurement error which can lead to “information bias.” The overwhelming majority of information bias in epidemiologic studies of formaldehyde stems from the use of occupational records to gauge exposures with some degree of exposure misclassification or exposure measurement error considered to be commonplace.

A primary consideration in the evaluation of these studies is the ability of the exposure assessment to reliably distinguish among levels of exposure within the study population, or between the study population and the referent population. A large variety of occupations are included within the studies; some represent work settings with a high likelihood of exposure to high levels of formaldehyde, and some represent work settings with variable exposures and in which the proportion of people exposed is quite small. In the latter case, the potential effect of formaldehyde would be “diluted” within the larger study population, limiting the sensitivity or informative nature of the study. EPA categorized the exposure assessment methods of the identified studies into four groups (A through D), reflecting greater or lesser degree of reliability and sensitivity of the measures (see Table B-55).

For cohort studies and nested case-control studies within cohort studies, the category of Exposure Group A included studies in industrial settings with extensive industrial hygiene data used to determine levels of exposure (and variability within a worksite); and a job exposure matrix that accounts for variability by time and job/task. This category also included studies with highly exposed professions (embalmers) with comparison to the general population, or with measures capturing variability within the cohort. For case-control studies, the category of Exposure Group A included studies with detailed lifetime job history, more extensive than industry and occupation codes, including information about specific tasks and setting, combined with job exposure matrix that accounts for variability by time, setting, and job/task. Also includes some kind of validation study or congruence of ratings based on different exposure ascertainment measures to be equivalent to Group A cohort studies with extensive industrial hygiene data.

For cohort studies and nested case-control studies within cohort studies, the category of Exposure Group B included studies with industrial settings with more limited industrial hygiene data. This category also included studies with exposed professions (e.g., pathologists) with comparison to general population, but that do not have measures capturing variability within the cohort. For case-control studies, the category of Exposure Group B included studies with detailed lifetime job history, more extensive than industry and occupation codes, including information about specific tasks and setting, combined with job exposure matrix that accounts for variability by time, setting, and job/task.

For cohort studies and nested case-control studies within cohort studies, the category of Exposure Group C included studies with industrial settings that are only able to use duration as a way to distinguish variability in exposure and studies with self-report of exposure. For case-control studies, the category of Exposure Group C included studies with lifetime job history coding based only on industry and occupation; more detailed information about specific tasks and setting not included in assessment of exposure potential (or, information on what was collected was not provided). This category also included studies with self-report of exposure; and, studies with lifetime job history, including tasks/exposure information, but analysis conducted only for job categories rather than for an exposure category.

For cohort studies and nested case-control studies within cohort studies, the category of Exposure Group D included studies industrial settings that do not include data to distinguish variability in exposure (e.g., wood workers, with no information on which workers were exposed to formaldehyde; textile workers with no formaldehyde exposure measures), or that include few people classified as exposed. For case-control studies, the category of Exposure Group C included studies with Job history limited to information on a single job (e.g., based on tax record, death certificate, medical record, census data). This category also included studies with a high proportion of next-of-kin interviews (>40%).

Outcome-specific association based on Group A exposures were consider without appreciable information bias due to exposure measurement error while those based on Groups B–D were considered to be somewhat biased towards the null. The categorization of the exposure assessment methods for the assessed studies are documented in Appendix B.3.9.

Additional exposure measurement error may arise in circumstances when the time period of exposure assessment is not well aligned with the time period when formaldehyde exposure could induce carcinogenesis that develops to a detectable stage (incident cancer) or result in death from a specific cancer. Epidemiology studies regularly explore the analytic impact of different lengths of ‘latency periods’ which may exclude from the analyses the formaldehyde exposure most proximal to each individual’s cancer incidence or cancer mortality. For analyses of the exposure-related risks of solid tumors, it is commonplace to evaluate latency periods of 10, 15, or 20 years by presenting results stratified by time since first exposure or to exclude (or in the parlance of epidemiology, to “lag”) exposures in the 10, 15, or 20 years immediately prior to death from the analyses so as to more accurately (potentially) describe what may be the more biologically relevant window of exposure in time that could have caused carcinogenesis (sometimes called the etiologically relevant time period). Analyses which do not evaluate latency may be inducing exposure measurement error by including irrelevant exposure and were considered to be somewhat biased towards the null.

An understanding of the effects of exposure measurement error on the results from epidemiologic analyses is important as it enables the reviewer to place these possible exposure measurement errors in context. The effect of exposure measurement error on estimates of the risk of cancer mortality potentially attributable to formaldehyde exposure depends upon the degree to which that error itself may be related to the likelihood of the outcome of interest. Exposure measurement error that is similar among both workers who died of a specific cancer, and those who did not die of that cancer, is termed nondifferential exposure measurement error. Exposure measurement error that is associated with the outcome (error that is differential with respect to disease status) can cause bias in an effect estimate towards or away from the null, while nondifferential exposure error typically results in bias towards the null (Rothman and Greenland, 1998).

4) Outcome measure

The diagnosis of cancers in epidemiologic studies has historically been ascertained from death certificates according to the version of the International Classification of Diseases (ICD) in effect at the time of study subjects’ deaths [i.e., ICD-8 and ICD-9: (WHO, 1967, 1977)]. The most specific classification of diagnoses that is commonly reported across the epidemiologic literature has been based on the first three digits of the ICD code (i.e., Myeloid Leukemia ICD-8/9: 205) without further differentiation (i.e., Acute Myeloid Leukemia ICD-8/9: 205.0)—although some studies have reported results at finer levels. In the evaluation of the epidemiologic evidence for upper respiratory cancers, four different types are reviewed: sinonasal cancer, nasopharyngeal cancer, oro/hypopharyngeal cancer, and laryngeal cancer. In the evaluation of the epidemiologic evidence for LHP cancers, four different subtypes are reviewed: myeloid leukemia (including monocytic leukemia), lymphatic leukemia, multiple myeloma, and Hodgkin lymphoma. In restricting the causal evaluation of LHP cancers to these four specific subtypes, another category of LHP cancer originating from white blood cells, which includes all lymphoma not classified as Hodgkin, was not evaluated.

In the review of study quality for cancer studies, the outcome measure was generally considered to be accurate as the source of this information was typically from death certificates, cancer registries, or hospitals. Some studies did provide additional information on histological typing, but the majority did not. Histological type can be informative in understanding the epidemiologic evidence, but the lack of such information was not judged as a major study limitation. While it is true that death certificates and other administrative records can occasionally contain errors, the impact of misclassification of outcome on epidemiologic results is to reduce precision in effect estimates and not to induce bias.

5) Consideration of likely confounding

EPA evaluated the potential for confounding based on exposures to identified risk factors for specific, or related, cancers, whether those exposures were found to be risk factors in the specific study and whether there was a known or likely correlation between those exposures and formaldehyde. Information on the presence of potential confounders in a particular study was gleaned from the study itself or from information from outside the study (e.g., information on exposure levels from other sources).

Risk factors for LHP cancers include pharmaceuticals (chemotherapeutic drugs), biological agents (e.g., viruses), radiation, and chemical exposures (Cogliano et al., 2011). The primary agents of interest that were considered in the study quality review are the potential occupational and environmental co-exposures that may be associated with formaldehyde exposure as well as LHP cancers. Chemotherapeutic drug exposures were not expected to be correlated with formaldehyde exposures during the etiologically relevant time period for potentially formaldehyde-related carcinogenesis and were not considered as potential confounders. Similarly, viral exposures and radiation exposures also were not expected to be correlated with formaldehyde exposures except, possibly, among embalmers and pathologists who may be co-exposed by deceased persons who had viral infections or had implanted radiation devices used in chemotherapy. Each of the chemical and occupational exposures that were reported to be associated with risks of LHP cancers (i.e., benzene, 1,3-butadiene, 2,3,7,8-tetrachlorodibenzo-para-dioxin, ethylene oxide, magnetic fields, paint, petroleum refining, polychlorophenols, radioisotopes and fission decay products, styrene, tetrachloroethylene, tobacco smoking, trichloroethylene; (Cogliano et al., 2011) was examined in the study quality review and evaluated as a potential confounder of any association between formaldehyde and specific LHP cancers.

Risk factors for URT cancers include biological agents (e.g., viruses), radiation, and chemical exposures (Cogliano et al., 2011). As described above, viral exposures and radiation exposures also were not expected to be correlated with formaldehyde exposures except, possibly, among embalmers and pathologists who may be co-exposed by deceased persons who had viral infections or had implanted radiation devices used in chemotherapy. Each of the chemical and occupational exposures which were reported to be associated with risks of URT cancers (i.e., acid mists, asbestos, chromium VI, isopropyl alcohol production, leather dust, nickel compounds, radioisotopes and fission decay products, rubber production, textile manufacturing, tobacco smoking, and wood dust (Cogliano et al., 2011)) was examined in the study quality review and evaluated as a potential confounder of any association between formaldehyde and specific URT cancers.

The specific chemical and occupational exposures listed above, which were reported to be associated with LHP or URT cancers are bolded in the lists of co-exposures in each study in the Exposure Measure column of the study evaluation documentation tables in Appendix B.3.9. This identifies any important co-exposures which are then evaluated for their potential correlation with formaldehyde exposure to identify potential confounders.

6) Analysis and results (estimate and variability)

Analyses should be appropriate with respect to study design. When analytic methods are not matched to the study design, the expected impact on the results was evaluated. For cancer endpoints, results that examined the effects of including various latency periods using lagged exposure of strata of time since first exposure allow for the focus of results on different etiological windows of time that may be more biologically relevant. Studies that did not report results looking at different latencies may be vulnerable to additional exposure measurement error as they evaluate the effects of formaldehyde exposures during times that may not have any causal effects such as in the years immediately preceding death.

7) Study sensitivity

In addition to potential bias, study sensitivity was specifically evaluated; study results with low sensitivity could result in effect estimates that underestimated a “true” association if it existed. Cohort studies should have a sufficiently long follow-up period to allow for any exposure-related cancer cases to develop and be detected and, ideally, allow for analyses of potential cancer latency. Outcome-specific effect estimates from cohort studies with short follow-up could be considered uninformative depending on the size of the study population and the baseline frequency of the cancer. Studies with small cases counts may have little statistical power to detect divergences from the null but are not necessarily expected to be biased and no study is excluded solely on the basis of cases counts as this methodology would exclude any study which saw no effect of exposure. Therefore, cohort studies with extensive follow-up which reported outcome-specific results on a number of different cancers, including very rare cancers such as NPC and SNC, are evaluated even when few or even no cases were observed, if information on the expected number of cases in the study population was provided so that confidence intervals could be presented to show the statistical uncertainty in the associated effect estimated. For example, Coggon et al. (2014) followed the mortality of 14,008 workers and yet expected only 1.7 deaths from nasopharyngeal cancer in the exposed workers and observed just one resulting in an unstable estimated RR=0.38 (95% CI: 0.02–1.90). Meyers et al. (2013) followed the mortality of 11,043 workers and expected only 1.33 deaths from nasopharyngeal cancer and did not observe any deaths, resulting in a SMR=0 (95% CI: 0–2.77). These studies were included in the evidence syntheses, but the limitation relating to size and resulting sensitivity was noted.

Another example of low sensitivity would be a study that might have relied on exposure-assessment methodologies that were unbiased, but were nonspecific in nature, so as to yield effect estimates that were likely biased toward the null and thus underestimated any true effect. In general, cohort studies should have a sufficiently long follow-up period for any exposure-related cancer cases to develop and be detected and ideally, allow for analyses of potential cancer latency. Outcome-specific effect estimates from cohort studies with short follow-up could be uninformative depending on the size of the study population and the baseline frequency of the cancer.

The outcome-specific confidence classifications for each study and cancer endpoint combination, as well as the individual domain evaluations are documented in Appendix B.3.9; as with other outcomes, the studies identified as not informative are not discussed in the Toxicological Review.

#### Cancer Studies in Animals

##### Respiratory tract cancers

All subchronic or chronic studies (and an 8-week exposure study in potentially vulnerable mice) in experimental animals that included histopathological evaluations of respiratory tract tissues (i.e., nose/nasal cavity, larynx, trachea, lung) were evaluated (see Appendix B.3.9), noting that evaluations of the pharynx or mouth were uncommon in these studies, probably because experimental rodents are obligate nose-breathers). Histopathological evaluations used standard cross-section levels of the nasal passages that paralleled the evaluations of respiratory tract pathology described in Section 2.3.5.

In addition to the general considerations outlined in Section 2.1, criteria specific to evaluating respiratory tract cancer were evaluated (see Table 2-37). With one exception (see synthesis in Section 3.2.5), studies of experimental animals exposed for at least subchronic duration (shorter exposure durations were not considered informative to this endpoint, given the robust database), and which performed histopathological evaluations of respiratory tract tissues, were evaluated. As these evaluations consider many of the same studies previously evaluated for inclusion in the noncancer respiratory tract pathology section (see Section 2.3.5), many parallels exist between both sets of evaluations. While the important considerations across the two sections are generally similar, several notable differences exist. For example, duration of exposure was seen as more important for evaluations of dysplasia and neoplasms, as compared with evaluations of noncancer respiratory tract lesions. Conversely, whereas a substantial emphasis was placed on the characterization of the severity of the lesion for noncancer respiratory tract changes, severity was not considered integral to the identification of cancers and dysplasia. Finally, although most studies of respiratory pathology used paraformaldehyde or freshly prepared formalin as the test article, some studies tested commercial formalin. While co-exposure to methanol is a major confounding factor for systemic endpoints, it is considered to be less of a concern when identifying effects of inhaled formaldehyde on respiratory pathology. Because of the abundance of animal respiratory pathology studies, only those ranked as having “Good” or “Adequate” exposure quality, and several ranked as having “Deficient” exposure quality studies solely because they tested formalin (see evaluations in Appendix B.3.9), were included in the synthesis for respiratory tract cancers. Additional considerations that might influence the interpretation of the usefulness of the studies during the hazard synthesis are noted, including limitations such as the use of only one test concentration or concentration that are all too high or too low to provide a spectrum of the possible effects, as well as study strengths such as very large sample sizes or use of good laboratory practices (GLP); however, this information did not affect the study evaluation decisions.

Table 2-37 Criteria for categorizing study confidence in animal studies of respiratory tract cancers

Evaluation domain | Overview of preferred study features | Primary criteria for domain ratings (Documentation shorthand used in Appendix B.3.9)
Evaluation domain | Overview of preferred study features | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Exposure Quality | Well-characterized and appropriate inhalation exposure conditions (See methods in Section 2.3.1, applied consistently across experimental studies; see documentation in Appendix B.3.1). Studies without tested exposure <15 mg/m^3^ are flagged as such. | - “Good” Exposure Quality; [Note: for POE endpoints such as this, methanol co-exposure was not a major concern] | - “Adequate” Exposure Quality or “Deficient” Exposure Quality if the driver of the domain rating was use of formalin (i.e., this was not considered a critical deficiency for this POE effect) | - “Deficient” Exposure Quality not based on use of formalin as the test article; [Note: interpretation of the exposure levels is discussed in the hazard synthesis and is not, on its own, a reason for deficient]
Test Subjects | Sample size provides reasonable power to assess endpoint(s) in question (e.g., >20/group desired); species, strain, sex, & age relevant to endpoint; no overt systemic toxicity noted or expected | - Chronic study: N ≥ 20 (note: for this outcome, testing only one sex not a limitation); - Details on test subjects reported; - Randomization preferred (but not required); - Mortality unlikely to interfere with interpretations | - Generally, N < 20; - Individual less essential test subject details (e.g., sex) unclear; - High mortality complicates interpretation | - Generally, N < 10; - Multiple less essential study details (e.g., sex, strain) unclear; - Individual essential study detail (e.g., species) unclear; - High mortality prevents interpretation or mortality NR
Study Design | The study design is appropriate and informative for evaluating respiratory tract cancer or dysplasia, including a sufficient exposure duration and/or appropriate timing of endpoint evaluations to allow for cancer to develop, and a lack of additional modifying variables introduced over the course of the study. GLP-compliant studies are highlighted | - Long-term exposure (e.g., ^~^2 years in rodents) to allow for cancer to develop; - Exposure periodicity and frequency appropriate; - No evidence of potential confounding | - Exposure duration < 1 year with long-term follow-up; - Minor concerns with confounding, or exposure periodicity or frequency | - Exposure duration < 1 year without long-term follow up; - Factors likely to introduce confounding identified; - Exposure periodicity or frequency likely to be insensitive (e.g., brief, intermittent exposures)
Endpoint Evaluation | The protocols used to assess respiratory tract cancer or dysplasia are sensitive and complete (e.g., multiple tissues and sections examined), discriminating (specific), & biologically sound (reliable); experimenter bias minimized (e.g., slides blinded to evaluator) | - Pathology evaluations blinded; - Sufficient sampling for coverage of URT tissues (and preferably including distal respiratory tissues); - Evaluation methods reported (including number and region of tissue sections, number of slides, etc.) | - Blinding not reported (only a minor limitation for these endpoints, as the pathology is expected to be overt and not reliant on subtle decisions that would be impacted by evaluator biases); - Minor limitations in reporting of evaluation methods; - Limited sampling (e.g., only nasal cavity; only a few slides; only a subset of URT tissue locations; only certain lesion types considered) | - Multiple limitations (see ‘adequate’ column at left); - Key URT tissues (e.g., nasal cavity) not examined; - Insensitive protocols used (e.g., multiple tissues and sections were not examined); - Protocols otherwise critically flawed
Data considerations and statistics | Statistical methods are reported, group comparisons and data/variability presentation are appropriate & discerning; mortality data are described | - Adequate reporting and presentation of results; - No evidence of selective reporting; - Statistical methods described | - Failure to report statistical analyses; - Concern regarding selective reporting; - Concern with presentation of results (e.g., pooling of lesions or incidence data); - Lack of clarity of reported data (e.g., unclear anatomical location of lesions; qualitative or example-based reporting) | - Failure to report enough data to interpret reported findings; - Multiple limitations (see ‘adequate’ column at left)

##### Lymphohematopoietic cancers

Studies examining LHP cancers were evaluated using nearly identical approaches and criteria as those for respiratory cancers (above). Given the assumed differential distribution of inhaled formaldehyde as compared to exposure by other routes, only inhalation studies were considered relevant to the review of LHP cancers in animals. Detailed study evaluation tables of the four relevant inhalation studies are available in Appendix B.3.9. One notable difference from the evaluation of respiratory tract cancers involved consideration of the test article as a key component of the review, as co-exposure to methanol in studies using formalin could have a substantial impact on the interpretation of potential LHP cancers (see exposure quality evaluation in Appendix B.3.1). A minor difference involved the preference for microscopic examination of several tissues applicable to assessing potential LHP cancers.

Table 2-38 describes the criteria for domain ratings used to inform confidence classifications for animal studies of LHP cancers.

Table 2-38 Criteria for categorizing study confidence in animal studies of lymphohematopoietic (LHP) cancers

Evaluation domain | Overview of preferred study features | Primary criteria for domain ratings (Documentation shorthand used in Appendix B.3.9)
Evaluation domain | Overview of preferred study features | Good (‘++’) | Adequate (‘+’) | Deficient (‘gray’)
Exposure Quality; [Note: for systemic endpoints such as this, methanol co-exposure is a major concern] | Well-characterized and appropriate inhalation exposure conditions (See methods in Section 2.3.1, applied consistently across experimental studies; documentation in Appendix B.3.1). Studies without tested exposure <15 mg/m^3^ are flagged as such. | - “Good” Exposure Quality; - Co-exposures unlikely | - “Adequate” Exposure Quality; - Co-exposure likely but controlled (e.g., methanol control group with formalin exposure) | - “Deficient” Exposure Quality; - Uncontrolled co-exposure likely; [Note: formaldehyde levels are discussed in the synthesis and high levels are not a reason for deficient]
Test Subjects | Sample size provides reasonable power to assess endpoint(s) in question (e.g., >20/group desired); species, strain, sex, & age relevant to endpoint; no overt systemic toxicity noted or expected | - Chronic study: N ≥ 20 (note: for this outcome, testing only one sex not a limitation); - Details on test subjects reported; - Randomization preferred (but not required); - Mortality unlikely to interfere with interpretations | - Generally, N < 20; - Individual less essential test subject details (e.g., sex) unclear; - High mortality complicates interpretation | - Generally, N < 10; - Multiple less essential study details (e.g., sex, strain) unclear; - Individual essential study detail (e.g., species) unclear; - High mortality prevents interpretation or mortality NR
Study Design | The study design is appropriate and informative for evaluating respiratory tract cancer or dysplasia, including a sufficient exposure duration and/or appropriate timing of endpoint evaluations to allow for cancer to develop, and a lack of additional modifying variables introduced over the course of the study. GLP-compliant studies are highlighted | - Long-term exposure (e.g., ^~^2 years in rodents) to allow for cancer to develop; - Exposure periodicity and frequency appropriate; - No evidence of potential confounding | - Exposure duration < 1-year with long-term follow-up; - Minor concerns with confounding, or exposure periodicity or frequency | - Exposure duration < 1 year without long-term follow up; - Factors likely to introduce confounding identified; - Exposure periodicity or frequency likely to be insensitive (e.g., brief, intermittent exposures)
Endpoint Evaluation | The protocols used to assess respiratory tract cancer or dysplasia are sensitive and complete (e.g., multiple tissues and sections examined), discriminating (specific), & biologically sound (reliable); experimenter bias minimized (e.g., slides blinded to evaluator) | - Pathology evaluations blinded; - Sufficient sampling for coverage of LHP tissues, including bone marrow; - Evaluation methods reported (including number and region of tissue sections, number of slides, etc.) | - Blinding not reported; - Minor limitations in reporting of evaluation methods; - Limited sampling (e.g., one or few tissues; only certain lesion types considered; only certain tissues or exposure levels microscopically examined) | - Multiple limitations (see ‘adequate’ column at left); - Key LHP tissues (e.g., bone marrow) not examined; - Only gross lesions quantified (i.e., no microscopic examinations)
Data considerations and statistics | Group comparisons, & data/variability presentation are appropriate & discerning; mortality data and statistical methods are clearly described | - Adequate reporting and presentation of results; - No evidence of selective reporting; - Statistical methods described | - Failure to report statistical analyses; - Concern regarding selective reporting; - Concern with presentation of results (e.g., pooling of lesions or incidence data); - Lack of clarity of reported data (e.g., unclear anatomical location of lesions; qualitative or example-based reporting) | - Failure to report enough data to interpret findings (e.g., incidence data, or lack of any tumors, not reported); - Multiple limitations (see ‘adequate’ column at left)

### 2.3.10 Study Evaluation Criteria for Mechanistic Information Related to Genotoxicity and Cancer

#### Approaches for Cancer Mode of Action

Consolidated, formal systematic approaches to evaluating the studies examining mechanistic data relevant to interpreting the potential for formaldehyde to cause either upper respiratory tract (URT) or lymphohematopoietic (LHP) cancers were not performed. Rather, these sections build from studies identified and evaluated through other health effect-specific literature searches and consider those studies in the context of the specific cancer etiology being reviewed alongside other relevant studies (e.g., those identified as described in Section 2.2.10). This includes supplemental literature relevant to interpreting the biological relevance of some mechanistic data from review articles and other national-level health assessments. Specifically, these sections rely heavily on searches and evaluations performed in the following sections: genotoxicity (see below), respiratory tract pathology (see Section 2.3.5), and mechanistic information related to noncancer respiratory effects, focusing on inflammation and immune effects (see Section 2.3.6). Studies identified outside of these specific searches (e.g., from reviews) were not individually evaluated. Rather, as described in Section 2.3.1, these studies were considered within the wider body of evidentiary support (or lack thereof) for specific, influential mechanistic events (e.g., those known to be associated with the cancer type of interest; those previously implicated in authoritative reviews as relevant to interpreting formaldehyde exposure-induced carcinogenicity), with judgments based on overarching interpretations across the different sets of inter-related studies using structured frameworks for the evaluations based on EPA’s Cancer Guidelines (U.S. EPA, 2005a) (see Sections 3.2.5 and 3.3.3).

#### Genotoxicity-Specific Evidence Evaluation

Epidemiological studies examining genotoxic endpoints were evaluated for potential bias and other issues using the same domains as were assessed for studies in other health effects categories (i.e., exposure measures and range; outcome classification; consideration of participant selection and comparability; consideration of likely confounding; analysis and completeness of results; and study size). Rather than confidence conclusions of low, medium, or high, an overall conclusion of “no obvious bias” was used if no concerns were identified; this equates to classifications of high or medium confidence. For studies with a potential bias identified, the potential bias or issue was summarized in the comment row. For each assay (e.g., chromosomal aberrations, CBMN, Comet assay), factors related to assay methods that could affect the endpoint values were identified using published reviews from collaborations that compared assay methods across epidemiological studies (Valverde and Rojas, 2009; Møller et al., 2020; Fenech et al., 2011; Fenech, 2020; Bonassi et al., 2005; Bonassi et al., 2011). Such factors included sample collection and processing flows, whether sample processing and analysis was blinded to exposure status, cell culture details, details of scoring (number of scorers, criteria, staining, number of cells scored). An appropriate citation to a standardized assay protocol was considered acceptable. These reviews noted that assay results have been found to vary by age, gender, and smoking status; studies that did not report assessing confounding by these factors were identified. In the study evaluation table for each study, row cells have been given a gray fill for evaluation domains with identified concerns about methods. Study evaluation concerns are discussed in the syntheses of genotoxic endpoints if they may explain observed heterogeneity in study results. The study-specific evaluations are documented in Appendix B.3.10.

## 2.4 DATA EXTRACTION METHODS

Data extraction and content management were carried out using Microsoft Word and Excel except for studies captured in the 2021 SEM, which also used EPA’s Health Assessment Workspace Collaborative (HAWC). Study details are documented primarily in evidence tables within the evidence synthesis sections (Section 3). Studies evaluated as being not informative are not used in the assessment and study details are not provided. The same is true in some cases for low-confidence studies when many medium- and high-confidence studies were available, unless the low-confidence studies included study designs lacking in the higher confidence studies (e.g., testing lower exposure levels, or susceptible populations or lifestages). Data extraction was performed by one member of the evaluation team and checked by at least one other member.

## 2.5 EVIDENCE SYNTHESIS METHODS

Section 3 includes evidence syntheses for the following health hazard categories: sensory irritation; reduced pulmonary function, respiratory tract pathology, immune-mediated conditions, focusing on allergies and asthma; cancer (respiratory tract cancers, lymphohematopoietic cancers); nervous system effects (motor neuron disease, tests of general motor-related behaviors, neural sensitization, learning or memory, neuropathology); developmental and female reproductive toxicity; and male reproductive toxicity. Health hazard categories were chosen based on prior reviews, as well as the specifics of the available literature. The units of analysis within an overall hazard category for which a hazard conclusion was developed were determined based on biologic considerations (i.e., specific to an organ system and considering the degree to which endpoints are related) and the number of studies that evaluated a particular outcome. Thus, hazard conclusions were developed for consolidated sets of related health endpoints within an overall hazard category in some instances (e.g., male reproductive toxicity).

For each unit of analysis (hazard category, or hazard subgrouping), and depending on the data available, separate syntheses were developed for each of the three streams of evidence: namely, human health effect studies, animal health effect studies, and mechanistic studies. These evidence syntheses, which incorporate the evaluations of the strengths and limitations of the available studies as well as considerations related to the toxicokinetics of inhaled formaldehyde, provide a discussion of the information provided by each stream of evidence regarding the potential for exposure to formaldehyde via inhalation to result in specific health effects. All high, medium, and low confidence studies (see Section 2.3.1), regardless of the magnitude or direction of results (i.e., whether yielding positive or null results) were considered in assessing the evidence; however, the focus of the synthesis was on the high and medium confidence studies, when available. Descriptive information about study methods and detailed results are generally presented in tabular or graphical displays, with supportive text. The narrative summaries discuss the nature and breadth of the available literature, highlighting details that contribute to the analysis of the strength of evidence regarding causality in the next section. In addition, to the extent the data allow, based on knowledge about the health outcome or organ system affected, the syntheses discuss analyses relating to potential susceptible populations, including factors such as demographics, genetic variability, lifestage, health status, behaviors or practices, social determinants, and exposure to other pollutants. This information informs both hazard identification and dose-response analyses.

The syntheses of the separate streams of evidence—human health effect studies, animal health effect studies, and mechanistic studies—involved consideration of a related set of factors, the evaluation of which differed due to the nature of the study designs and applicability of the data. Specifically, the syntheses inform an adapted set of considerations based on those introduced by Austin Bradford Hill (Hill, 1965), including consistency, exposure-response relationship, strength of the association (magnitude of effect) and precision, biological plausibility, and coherence, as well as “natural experiments” in humans (U.S. EPA, 1994, 2005a), as described in Table 2-39.

Table 2-39 Information most relevant to describing primary factors informing causality during evidence syntheses

Factor | Description and synthesis methods
Consistency | - Examines the similarity of results (e.g., direction; magnitude) across studies.; When inconsistencies exist, the synthesis considers whether results were “conflicting” (i.e., unexplained positive and negative results in similarly exposed human populations or in similar animal models) or “differing” (i.e., mixed results explained by differences between human populations, animal models, exposure conditions, or study methods) (U.S. EPA, 2005a) based on analyses of potentially important explanatory factors such as:; - Confidence in studies’ results, including study sensitivity (e.g., some study results that appear to be inconsistent may be explained by potential biases or other attributes that affect sensitivity, resulting in variations in the degree of confidence accorded to the study results); - Exposure, including route (if applicable), levels, duration, etc.; - Populations or species, including consideration of potential susceptible groups or differences across lifestages at exposure or endpoint assessment.; - Toxicokinetic information as an explanation for any observed differences in responses across route of exposure, other aspects of exposure, species, or lifestages; The interpretation of the consistency of the evidence and the magnitude of the reported effects will emphasize biological significance as more relevant to the assessment than statistical significance. Statistical significance (as reported by p-values, etc.) provides no evidence about effect size or biological significance, and a lack of statistical significance will not be automatically interpreted as evidence of no effect.
Strength (effect magnitude) and precision | - Examines the effect magnitude or relative risk, based on what is known about the assessed endpoint(s), and considers the precision of the reported results based on analyses of variability (e.g., confidence intervals; standard error). In some cases, this may include consideration of the rarity or severity of the findings (in the context of the health effect being examined).; Syntheses will analyze results both within and across studies and may consider the utility of combined analyses (e.g., meta-analysis). While larger effect magnitudes and precision (e.g., p < 0.05) help reduce concerns about chance, bias, or other factors as explanatory, syntheses should also consider the biological or population-level significance of small effect sizes.
Biological gradient/dose-response | - Examines whether the results (e.g., response magnitude, incidence, severity) change in a manner consistent with changes in exposure (e.g., level, duration), including consideration of changes in response after cessation of exposure.; Syntheses will consider relationships both within and across studies, acknowledging that the dose-response (e.g., shape) can vary depending on other aspects of the experiment, including the outcome and the toxicokinetics of the chemical. Thus, when dose-response is lacking or unclear, the synthesis will also consider the potential influence of such factors on the response pattern.
Coherence | - Examines the extent to which findings are cohesive across different endpoints that are known/expected to be related to, or dependent on, one another (e.g., based on known biology of the organ system or disease, or mechanistic understanding such as toxicokinetic/dynamic understanding of the chemical or related chemicals). In some instances, additional analyses of mechanistic evidence from research on the chemical under review or related chemicals that evaluate linkages between endpoints or organ-specific effects may be needed to interpret the evidence. These analyses may require additional literature search strategies.; Syntheses will consider potentially related findings, both within and across studies, particularly when relationships are observed within a cohort or within a narrowly defined category (e.g., occupation, strain or sex, lifestage of exposure). Syntheses will emphasize evidence indicative of a progression of effects, such as temporal- or dose-dependent increases in the severity of the type of endpoint observed.
Mechanistic evidence related to biological plausibility | - There are multiple uses for mechanistic information (see Section 2.5.1), and this consideration overlaps with “coherence.” This examines the biological support (or lack thereof) for findings from the human and animal health effect studies and becomes more impactful on the hazard conclusions when notable uncertainties in the strength of those sets of studies exist. These analyses can also improve understanding of dose- or duration-related development of the health effect. In the absence of human or animal evidence of apical health endpoints, the synthesis of mechanistic information will drive evidence integration conclusions (when such information is available).; Syntheses can evaluate evidence on precursors, biomarkers, or other molecular or cellular changes related to the health effect(s) of interest to describe the likelihood that the observed effects result from exposure. This will be an analysis of existing evidence, and not simply whether a theoretical pathway can be postulated. This analysis may not be limited to evidence relevant to the PECO but may also include evaluations of biological pathways (e.g., for the health effect; established for other, possibly related, chemicals). The synthesis will consider the sensitivity of the mechanistic changes and the potential contribution of alternative or previously unidentified mechanisms of toxicity.
Natural experiments | - Specific to epidemiological studies and rarely available, these examine effects in populations that have experienced well-described, pronounced changes in exposure to the chemical of interest (e.g., blood lead levels before and after banning lead in gasoline). No well-conducted natural experiments were identified for this chemical.

Consistency, magnitude of effects, and dose-response gradients were emphasized in the synthesis of results of epidemiological and controlled human exposure studies. The primary considerations for synthesizing the results of animal studies were consistency (e.g., across species and across research groups, with consideration of study confidence), magnitude and severity of the effects, dose-response, and coherence of findings for related effects. Although the precision of reported results could add to the strength of evidence for a health effect, results that are both statistically significant and nonsignificant are summarized. The syntheses focus on evaluating the potential sources of heterogeneity within sets of related studies to discern whether inconsistent evidence can be reasonably explained by the respective study designs or other empirical factors (U.S. EPA, 2005a). Consistency between studies was examined by comparing study results by confidence level, specific methodological features that contributed to potential bias, exposure setting, and level of exposure. The information from mechanistic studies in humans or animals relevant to each apical outcome was synthesized, highlighting information that could inform either biological plausibility, coherence, susceptibility, relevance to humans or an improved understanding of dose-response; these considerations are grouped under “other inferences” in the evidence profile tables and elsewhere and can inform evidence synthesis judgments (Section 2.5, Table 2-43), evidence integration conclusions (Section 2.6) or decisions related to dose-response analysis (Section 2.7). Approaches and considerations for the synthesis of mechanistic information are separately discussed in Section 2.5.1 below. Table 2-40 outlines the considerations for how the individual factors were evaluated to inform judgments about whether the formaldehyde-specific evidence increases or decreases the strength of the human or animal evidence for (or against) identifying a hazard.

Table 2-40 Primary considerations for assessing the strength of evidence for the health effects studies in human and, separately, animal studies^a^

Factor | Increased evidence strength; (of the human or animal study evidence) | Decreased evidence strength; (of the human or animal study evidence)
The structured categories and criteria in Tables VI and VII will guide the application of strength-of-evidence judgments for an outcome or health effect. Evidence synthesis scenarios that do not warrant an increase or decrease in evidence strength will be considered “neutral.”
Risk of bias; sensitivity (across studies) | - An evidence base of high or medium confidence studies increases strength. | - An evidence base of mostly low confidence studies decreases strength. An exception to this is when the primary issues resulting in low confidence are related to insensitivity. This may increase evidence strength in cases where an association is identified because the expected impact of study insensitivity is toward the null.; - Decisions to increase strength for other considerations in this table should generally not be made if there are serious concerns for risk of bias.
Consistency | - Similarity of findings for a given outcome (e.g., of a similar magnitude, direction) across independent studies or experiments increases strength, particularly when consistency is observed across populations (e.g., location) or exposure scenarios in human studies, and across laboratories, populations (e.g., species), or exposure scenarios (e.g., duration, route, timing) in animal studies. | - Unexplained inconsistency (conflicting evidence) decreases strength. Generally, strength should not be decreased if discrepant findings can be reasonably explained by study confidence conclusions, variation in population or species, sex, or lifestage, exposure patterns (e.g., intermittent, or continuous), levels (low or high), duration or intensity. However, any decisions about decreased strength will be determined by the extent to which residual questions about the evidence may persist.
Strength (effect magnitude) and precision | - Evidence of a large magnitude effect (considered within or across studies), can increase strength. Increases in rare effects or effects of a concerning severity can also increase strength, even if they are small in magnitude.; - Precise results from individual studies or across the set of studies increases strength, noting that biological significance is prioritized over statistical significance. | - The presence of small effects is not typically used to decrease confidence in a body of studies. However, if effect sizes that are small in magnitude are concluded not to be biologically significant, or if there are only a few studies with imprecise results, then strength is decreased.; - In animal studies, an example of evidence that can decrease strength involves an effect for which there is a lesser level of concern under some conditions (e.g., rapid reversibility after removal of exposure). Note that many reversible effects are of high concern. Such a decision is informed by factors such as the toxicokinetics of the chemical and the conditions of exposure (see U.S. EPA (1998)), judgments regarding the potential for delayed or secondary effects, as well as the exposure context focus of the assessment (e.g., addressing intermittent or short-term exposures).
Biological gradient/dose-response | - Evidence of dose-response increases strength. Dose-response may be demonstrated across studies or within studies and it can be dose or duration dependent. It may also not be a monotonic dose-response (monotonicity should not necessarily be expected), and the analysis will consider the extent to which this might be explained by the available evidence (e.g., different outcomes may be expected at low versus high doses due to activation of different mechanistic pathways or induction of systemic toxicity at very high doses).; - Decreases in a response after cessation of exposure (e.g., symptoms of current asthma) also may increase strength by increasing certainty in a relationship between exposure and outcome (this is applicable to human observational studies, but not experimental studies). | - A lack of dose-response when expected based on biological understanding and having a wide range of doses/exposures evaluated in the evidence base can decrease strength.; - In rare cases, and typically only in toxicology studies, the duration of exposure might reveal an inverse association with effect magnitude (e.g., due to tolerance or acclimation). Similar to the discussion of reversibility above, a decision about whether this decreases strength depends on the exposure context focus of the assessment and other factors.; - If the data are not adequate to evaluate a dose-response pattern, then strength is neither increased nor decreased.
Coherence | - Biologically related findings within an organ system, or across populations (e.g., sex) increase strength, particularly when a temporal- or dose-dependent progression of related effects is observed within or across studies, or when related findings of increasing severity are observed with increasing exposure. | - An observed lack of expected coherent changes (e.g., well-established biological relationships), particularly when observed for multiple related endpoints, will typically decrease evidence strength. The decision to decrease depends on the strength of the expected relationship(s), and considers factors (e.g., dose and duration of exposure) across studies of related changes.
Mechanistic evidence related to biological plausibility | - Mechanistic evidence of precursors or health effect biomarkers in well-conducted studies of exposed humans or animals, in appropriately exposed human or animal cells, or other relevant human or animal models (for the human or animal evidence, respectively) increases strength, particularly when this evidence is observed in the same cohort/population exhibiting the health outcome.; - Evidence of changes in biological pathways or providing support for a proposed MOA in models also increases strength, particularly when support is provided for rate-limiting or key events, or changes are conserved across multiple components of the pathway or MOA. | - Mechanistic understanding is not a prerequisite for judging the evidence, and thus absence of knowledge should not be used a basis for decreasing strength NTP (2015); NRC (2014a).The human relevance of animal findings is assumed unless there is sufficient evidence to the contrary [see U.S. EPA (2005a); IARC (2006)].; - Mechanistic evidence in well-conducted studies that demonstrates that the health effect(s) are unlikely to occur, or only likely to occur under certain scenarios (e.g., above certain exposure levels), can decrease evidence strength. A decision to decrease depends on an evaluation of the strength of the mechanistic evidence supporting vs. opposing biological plausibility, as well as the strength of the health effect-specific findings (e.g., stronger health effect data require more certainty in mechanistic evidence opposing plausibility).

a These ideas build upon the discussion for assessing causality of disease in Hill (1965), although the use or interpretation of some of the terms differs.

b While humans are “exposed” and not “dosed,” and nor are animals “dosed” via inhalation, “dose-response” is used for convention throughout the assessment, although it is acknowledged that ‘exposure-response’ may be more appropriate in many contexts.

c There is a clear overlap in the use of mechanistic evidence to interpret coherence (e.g., informing the relatedness or comparability of potentially coherent health findings) and biological plausibility. The available mechanistic information is also considered during the subsequent step of evidence integration across streams of evidence (see Section 2.6).

d Although it is not separately listed, Hill’s consideration of ‘analogy’ (information for a similar but different association that supports causation) is indirectly encompassed by the evaluation of coherence during the review of environmental health studies; however, this use of analogous chemicals or exposure scenarios is less common.

Summary synthesis judgments regarding the strength of the evidence from the available human and animal studies were drawn based on evaluation of the aforementioned factors. These judgments incorporated mechanistic evidence (or MOA understanding) in exposed humans and animals, respectively, that informed the biological plausibility and coherence of the available human or animal health effect studies, both of which could add to or detract from the strength of evidence, as described in Table 2-40 above. Note, however, that a lack of mechanistic data explaining an association did not discount results from human or animal health effect studies. Evidence synthesis judgments regarding the strength of the human and, separately, the animal evidence (with consideration of mechanistic information in humans and animals, respectively, including in vitro or other relevant models) for each noncancer health effect (or groups of related effects) and specific cancer type (or groups of related cancer types) was summarized using the following terms: robust, moderate, slight, indeterminate, and compelling evidence of no effect based on structured decision frameworks.

These decision frameworks, with criteria described in Tables 2-41 and 2-42, were used to apply expert judgment to weigh the strengths and weaknesses of both positive and null studies. These frameworks add clarity, consistency, and transparency to the evidence evaluations and conclusions; are consistent with generally accepted principles in epidemiology and toxicology; and are meant to convey a distribution of confidence in each body of evidence pertaining to a hazard. In addition to the synthesis narrative and summary strength of evidence judgment, the factors (e.g., consistency) providing the primary support for each judgment, and their summary justifications, are bulleted at the end of each evidence synthesis narrative in Section 3.

Table 2-41 Framework for strength of evidence judgments (human evidence)

Strength of evidence judgment | Description
Robust … evidence in human studies; (strong signal of effect with little residual uncertainty) | A set of high or medium confidence independent studies reporting an association between the exposure and the health outcome, with reasonable confidence that alternative explanations, including chance, bias, and confounding, can be ruled out across studies. The set of studies is primarily consistent, with reasonable explanations when results differ; an exposure-response gradient is demonstrated; and the set of studies includes varied populations. Additional supporting evidence, such as associations with biologically related endpoints in human studies (coherence) or large estimates of risk or severity of the response, may increase confidence but is not required.; In exceptional circumstances, a finding in one study may be considered to be robust, even when other studies are not available (e.g., analogous to the finding of angiosarcoma, an exceedingly rare liver cancer, in the vinyl chloride industry).; Mechanistic evidence from exposed humans or human cells, if available, may add support informing considerations such as exposure-response, temporality, coherence, and MOA, thus raising the level of certainty to robust for a set of studies that otherwise would be described as moderate.
Moderate … evidence in human studies; (signal of effect with some uncertainty) | A smaller number of studies (at least one high or medium confidence study with supporting evidence), or with some heterogeneous results, that do not reach the degree of confidence required for robust. For multiple studies, there is primarily consistent evidence of an association, but there may be lingering uncertainty due to potential chance, bias or confounding.; For a single study, there is a large magnitude or severity of the effect, or a dose-response gradient, or other supporting evidence, and there are not serious residual methodological uncertainties. Supporting evidence could include associations with related endpoints, including mechanistic evidence from exposed humans or human cells, if available, based on considerations such as exposure-response, temporality, coherence, and MOA, thus raising the level of certainty to moderate for a set of studies that otherwise would be described as slight.
Slight … evidence in human studies; (signal of effect with large amount of uncertainty) | One or more studies reporting an association between exposure and the health outcome, where considerable uncertainty exists. In general, only low confidence studies may be available, or considerable heterogeneity across studies may exist. Supporting coherent evidence is sparse. Strong biological support from mechanistic evidence in exposed humans or human cells may also be independently interpreted as slight. This also includes scenarios where there are serious residual uncertainties across studies (these uncertainties typically relate to exposure characterization or outcome ascertainment, including temporality) in a set of largely consistent medium or high confidence studies. This category serves primarily to encourage additional study where evidence does exist that might provide some support for an association, but for which the evidence does not reach the degree of confidence required for moderate.
Indeterminate … evidence in human studies; (signal cannot be determined for or against an effect) | No studies available in humans or situations when the evidence is inconsistent or primarily of low confidence
Compelling evidence of no effect … in human studies; (strong signal for lack of an effect with little uncertainty) | Several high confidence studies showing null results (for example, an odds ratio of 1.0), ruling out alternative explanations including chance, bias, and confounding with reasonable confidence. Each of the studies should have used an optimal outcome and exposure assessment and adequate sample size (specifically for higher exposure groups and for susceptible populations). The set as a whole should include the full range of levels of exposures that human beings are known to encounter, an evaluation of an exposure-response gradient, and an examination of at-risk populations and lifestages.

Table 2-42 Framework for strength of evidence judgments (animal evidence)

Strength of evidence judgment | Description
Robust … animal evidence | The set of high or medium confidence experiments includes consistent findings of adverse or toxicologically significant effects across multiple laboratories, exposure routes, experimental designs (e.g., a subchronic study and a two-generation study), or species, and the experiments can reasonably rule out the potential for nonspecific effects (e.g., indirectly due to overt toxicity at high exposure levels) to have resulted in the findings. Any inconsistent evidence (evidence that cannot be reasonably explained by the respective study design or differences in animal model) is from a set of experiments of lower confidence. At least two of the following additional factors in the set of experiments increases certainty in the evidence for the health outcome(s): coherent effects across multiple related endpoints (may include mechanistic evidence); an unusual magnitude of effect, rarity, age at onset, or severity; a strong dose-response relationship; or consistent observations across animal lifestages, sexes, or strains. Alternatively, mechanistic data in animals or animal cells that address the above considerations or that provide experimental support for a MOA that supports causality with reasonable confidence may raise the level of certainty to robust for evidence that otherwise would be described as moderate or, exceptionally, slight, or indeterminate.
Moderate … animal evidence | A set of evidence that does not reach the degree of certainty required for robust, but which includes at least one high or medium confidence study and information strengthening the certainty in the evidence for the health outcome(s). Although the results are largely consistent, notable uncertainties remain. However, while inconsistent evidence or evidence indicating nonspecific effects (e.g., toxicity) may exist, it is not sufficient to reduce or discount the level of concern regarding the positive findings from the supportive experiments or it is from a set of experiments of lower confidence. The set of experiments supporting the effect provide additional information supporting causality, such as consistent effects across laboratories or species; coherent effects across multiple related endpoints (may include mechanistic evidence); an unusual magnitude of effect, rarity, age at onset, or severity; a strong dose-response relationship; or consistent observations across exposure scenarios (e.g., route, timing, duration), sexes, or animal strains. Mechanistic data in animals or animal cells that address the above considerations or that provide information supporting causality with reasonable confidence may raise the level of certainty to moderate for evidence that otherwise would be described as slight.
Slight … animal evidence | Scenarios in which there is a signal of a possible effect, but the evidence is conflicting or weak. Most commonly, this includes situations where only low confidence experiments are available and supporting coherent evidence is sparse. It also applies when one medium or high confidence experiment is available without additional information increasing the certainty in the evidence (e.g., corroboration within the same study or from other studies). Lastly, this includes scenarios in which there is evidence that would typically be characterized as moderate, but inconsistent evidence (evidence that cannot be reasonably explained by the respective study design or differences in animal model) from a set of experiments of higher confidence (may include mechanistic evidence) exists. Strong biological support from mechanistic studies in exposed animals or animal cells may also be independently interpreted as slight. Notably, to encourage additional research, it is important to describe situations where evidence exists that might provide some support for an association but is insufficient for a conclusion of moderate.
Indeterminate …animal evidence | No animal studies were available, or a set of low confidence animal studies exist that are not reasonably consistent or are not informative to the hazard question under evaluation.
Compelling evidence of no effect … in animal studies | A set of high confidence experiments examining a reasonable spectrum of endpoints relevant to a type of toxicity that demonstrate a lack of biologically significant effects across multiple species, both sexes, and a broad range of exposure levels. The data are compelling in that the experiments have examined the range of scenarios across which health effects in animals could be observed, and an alternative explanation (e.g., inadequately controlled features of the studies’ experimental designs; inadequate sample sizes) for the observed lack of effects is not available. The experiments were designed to specifically test for effects of interest, including suitable exposure timing and duration, postexposure latency, and endpoint evaluation procedures, and to address potentially susceptible populations and lifestages.

### 2.5.1 Synthesis of Mechanistic Evidence

The mechanistic evidence syntheses inform multiple key decisions in the assessment, including the evidence synthesis judgments for human and animal studies (above), the evidence integration judgments for different health effect categories (Section 2.6), and decisions for dose-response analysis (Section 2.7). Examples of ways that mechanistic evidence is used to draw other inferences to inform the judgments drawn during evidence synthesis and integration (note: “other inferences” are described within the evidence profile tables in Section 3), and derivation of toxicity values, are described in Table 2-43. Given the exposure-related issues specific to formaldehyde and the abundance of data available, the mechanistic evaluations in this assessment focus almost exclusively on in vivo studies of inhalation exposures, with rare exception (e.g., evaluation of in vitro genotoxicity studies). As noted elsewhere (U.S. EPA, 2022), reflecting the increased scope and heterogeneity of the potentially relevant mechanistic information, the considerations and approaches used to synthesize and draw inferences about the mechanistic information differ from those used in synthesizing the human and animal health effect data; the specific approaches used in this assessment are summarized below.

Table 2-43 Examples of the interpretation and application of mechanistic evidence used to draw other inferences during evidence synthesis and integration, and dose-response analysis

Mechanistic inferences considered | Applications within the assessment
Biological plausibility: As applied herein, this applies to information that either strengthens or weakens an interpretation of the likelihood of an association between exposure and the health effect. Often, differing levels of biological plausibility (or certainty) can be drawn (i.e., it is often not a simple “yes” or “no” answer). It is important to note that the lack of mechanistic data explaining an association is not used to discount observations from human or animal studies. The interpretation of biological plausibility considers the existing knowledge for how the health effect develops and can involve analyses of information at different levels of biological organization (e.g., molecular, tissue). | Evidence Synthesis Judgments (Section 2.5); - Observations of important mechanistic changes in exposed humans or animals that are plausibly associated with the health outcome in question can strengthen the confidence in the health effect findings for either the human or animal evidence base, particularly when the changes are observed in the same exposed population presenting the health effect.; - Strong evidence supporting the absence of expected mechanistic changes in an exposed population might diminish the plausibility of an association. This considers the sensitivity of the changes and the potential contribution of alternative or unidentified toxicity mechanisms.; - Conflicting evidence (i.e., heterogeneous results for comparable mechanistic events using sufficiently similar methods) across different animal species or human populations might be explained by evidence that mechanisms differ or are not/less operant in the different populations (e.g., evidence demonstrating that certain animal species cannot metabolize a chemical to its reactive metabolite). Such analyses can also inform judgments regarding human relevance (see below).
Human relevance of findings in animals: In the absence of sufficiently justifiable mode of action (MOA) information, effects in animal models are assumed to be relevant to humans (U.S. EPA, 2005a). In this assessment, for potential health hazards where the evidence from animal models is likely to influence the overall hazard conclusion, the available mechanistic evidence was considered in light of human relevance. | Evidence Integration Judgments (Section 2.6); - Evidence establishing that the mechanisms underlying the animal response do not operate in humans, or that animal models do not suitably inform a specific human health outcome can support the view that the animal response is irrelevant to humans. In these cases, the animal response provides neither an argument for nor an argument against an overall hazard judgment.; - Observations of mechanistic changes in exposed humans that are similar or coherent with mechanistic or toxicological changes in experimental animals (and which are interpreted to be associated with the health outcome under evaluation) strengthen the human relevance of the animal findings.
Potential susceptibilities: When a mechanistic understanding of how a health outcome develops, or MOA, is known or hypothesized, knowledge about the presence and sensitivity (e.g., across lifestages), or modifying factors (e.g., genetics) of important events in that MOA can help identify susceptible groups. | Evidence Integration (Section 2.6); - Identification of susceptible lifestages or groups can add clarity to hazard descriptions regarding whether those most likely to exhibit effects have been adequately tested, or if large data gaps exist.; Dose-Response Analysis (Section 2.7); - Knowledge of potential or expected susceptibilities can inform selection of studies for quantitative analysis (e.g., prioritizing studies including such populations).; - Consideration of identified susceptible groups can inform uncertainty factor selection and confidence in toxicity values.
Biological understanding, including the identification of precursor events: When mechanistic data can reasonably describe how effects develop, this information may inform the situations or scenarios expected to result in these effects. Further, well-studied MOAs can sometimes identify mechanistic precursor events that can be qualitatively or quantitatively linked to the apical health effect in question with reasonable confidence. | Dose-Response Analysis (Section 2.7); - Understanding how effects develop might support the use of, for example, particular models (e.g., models assuming effects do not occur below certain levels; biologically based models; models integrating data across several closely related outcomes) or measures of exposure (e.g., different external or internal metrics).; - Uncertainty in the dose-dependence of responses in animals or humans can be influenced by the occurrence of precursor events, which can add to or subtract from the plausibility of the findings for use in dose-response analyses. Relatedly, in rare instances, well-established precursor events might be used as surrogates in dose-responses analyses when the health effect-specific data are less certain.

As described in Sections 2.2.10 and 2.3.10, consolidated systematic approaches to identifying and evaluating (and synthesizing) the mechanistic information relevant to interpreting the potential for formaldehyde to cause either upper respiratory tract (URT) or lymphohematopoietic (LHP) cancers were not performed. Rather, these syntheses intentionally addressed a broad collection of evidence built upon the other systematic reviews and pre-existing knowledge regarding the potential cancer mechanisms and precursor events related to inhaled formaldehyde. Consistent with the EPA cancer guidelines (U.S. EPA, 2005a) and approaches described in the IRIS Handbook (U.S. EPA, 2022), for both cancer type groupings, the findings were summarized and integrated into a proposed cancer MOA network that served as a framework for the evidence evaluation and MOA analysis. Like other sections, the evidence was synthesized following the Bradford Hill considerations, with an emphasis placed on observations following inhalation exposure in humans and experimental animals. The syntheses were developed in the context of carcinogenesis proceeding via one or more hypothesized, integrated cancer MOA(s), with alternative hypotheses examined.

The syntheses of the mechanistic information specifically informing noncancer health effects at systemic sites (i.e., developmental, and reproductive effects and nervous system effects) was much narrower, focusing on the few available medium and high confidence studies of inhalation exposure with relevant mechanistic information. To the extent the data allow, these syntheses focused on identifying mechanistic events^13^ in appropriate tissues that could be plausibly linked to the apical changes observed in the human or animal studies; speculative hypotheses without supporting data were avoided. The evidence bases were not extensive enough to conduct formal MOA analyses, but the strengths and uncertainties of the evidence supporting each potential mechanistic change were summarized.

Syntheses of mechanistic data that might inform potential noncancer respiratory health effects involved an integrated and systematic review process (see additional discussion below, detailed documentation in Appendix B.2.6 and B.3.6, and integrated analyses in Appendix C.7), which emphasized for each potential health effect the sequence(s) of mechanistic events interpreted to have the most reliable evidence, highlighting effects on specific tissue components and/or functions. Based on the known or presumed linkages, these events are organized from a “plausible initial effect of exposure” (e.g., a potential direct interaction between inhaled formaldehyde and biological materials) to each apical toxicity endpoint in a linear fashion, regardless of tissue region, and the summary MOA inferences are synthesized for each health effect in Section 3. Other mechanistic changes with less reliable information are summarized in Appendix C.7 only.

For these structured syntheses, due to the importance of considering the toxicokinetics of inhaled formaldehyde, the human and animal experiments interpreted with high or medium confidence and low confidence were organized according to the tissue compartment and general type of change being examined. Individual experiments or groups of closely related experiments across studies were divided into mechanistic events, representing empirically observable biological changes that may inform how formaldehyde exposure might be associated with a respiratory health effect(s). The level of evidentiary support for each mechanistic event was characterized as robust, moderate, slight, or indeterminate based on the criteria presented in Table 2-44. Similar to the factors emphasized during the human and animal health effect syntheses, these criteria emphasize the confidence and consistency of the data across studies. Other relevant considerations (e.g., effect magnitude, dose-response, coherence) are discussed when conclusions across studies could be drawn, but these judgments were often difficult due to the heterogeneous nature of the available mechanistic studies. Potential associations between mechanistic events were judged based on the tissue(s)/region(s) assessed and known biological roles within those tissues for the identified mechanistic events. The basis for each association was not individually documented; these are more generally discussed in the individual synthesis sections, or the study evaluation tables in Appendix B.3.6.

Table 2-44 Criteria and presentation of strength of the evidence for each mechanistic event and for potential associations between events relating to potential noncancer respiratory health effects

| Evidence judgment^a^ | Mechanistic events | | Associations between mechanistic events
| Evidence judgment^a^ | Criteria for conclusions | Presentation^b^ | Criteria for conclusions | Presentation^b^
Strongest | Robust | Direct evidence supporting an effect in multiple, consistent high or medium confidence studies^c^ | ◎; Emphasized in Syntheses | Formaldehyde-specific data demonstrate a linkage (i.e., inhibition of mechanistic event “A” prevents or reduces the occurrence of event “B”; events “A” and “B” are linked by concentration, location, or temporality) | →
| Moderate | Direct or indirect (e.g., genetic changes) evidence supporting an effect in at least one high or medium confidence study, with supporting evidence; (e.g., consistent changes suggesting an effect in low confidence studies)^b^ | ◯; Emphasized in Syntheses | - An association between events “A” and “B” is known based on established (basic) biology; - An association has been demonstrated for similar chemicals or effects | ⇢
| Slight | - Evidence supporting an effect in one hypothesis-generating high or medium confidence study; - Evidence suggesting an effect in multiple, reasonably consistent low confidence studies | ◌; Minimal Discussion in Syntheses | An association is justifiable, or even expected, based on underlying biology, but it has not been well established (note: events for which a biological association appears unlikely are not linked) | ⇢
Weakest | Indeterminate | - Evidence suggesting an effect in one low confidence study; - A set of low confidence studies with inconsistent results | Not included in figures; may be noted in synthesis text | N/A | N/A
Weakest | Indeterminate | - Evidence cannot be interpreted (no data; no pattern in results within or across studies); - Data suggest no change | Not included in figures or synthesis text | N/A | N/A

a For consistency, the words used to describe the judgments for apical health effect endpoints in human or animal studies were applied (see subsequent section, Evidence Integration and Confidence Conclusions for Noncancer and Cancer Health Outcomes), although the criteria herein are less rigorous (i.e., when evaluating sets of studies), unlike the conclusions for apical health effects.

b Supporting evidence and documentation for these decisions is provided in Appendix B.3.6 and C.7, with only the evidence on mechanistic changes (irrespective of the results) most informative to the health effect-specific discussions synthesized in Section 3.

c The presence of a comparable or stronger set of studies with directly conflicting evidence results in the identification of the next weaker evidence descriptor (e.g., robust evidence with conflicting data would be moderate); note that the purpose of this evaluation was not to identify mechanistic events for which there was robust evidence of no change; however, the plausibility of the pathways (considering evidence for a lack of changes in expected events) is discussed in later sections.

For the integrated MOA analyses on each potential health effect, the most informative data (i.e., preference is given to robust evidence) were synthesized across tissue compartments, with the discussion spanning those mechanistic events interpreted as the most likely to be due to (or most closely related to) direct interactions with inhaled formaldehyde molecules (i.e., “plausible initial effects of exposure”) to important apical toxicity endpoints (i.e., “key features of a potential hazard”, broadly representing the specific health effect findings observed in humans or animals). The health effect-specific syntheses sections are distilled from a broader network-based analysis of the interconnected mechanistic changes within and across tissue compartments, and across potential noncancer respiratory system health effects (see Appendix C.7 for the integrated analyses across the individually synthesized respiratory health effects) using an organizational structure similar to components of the adverse outcome pathway (AOP) approach (Villeneuve et al., 2014; Ankley et al., 2010). These distilled evidence syntheses attempt to simplify the data and emphasize the mechanistic events supported by the evidence interpreted with the highest confidence for each potential health effect, but they are not intended to convey most of the available information. They also only consider mechanistic events identified in formaldehyde-specific studies. These syntheses focus on generalized summary findings regarding the identified mechanistic events rather than observations in individual studies, and they include an overall summary interpretation regarding the biological plausibility of that sequence being a mechanism by which formaldehyde exposure might cause each noncancer respiratory health effects. Where data clearly suggest a dependence on exposure duration or exposure level to elicit an effect, these associations are discussed.

## 2.6 EVIDENCE INTEGRATION METHODS

For each unit of analysis or broader health effect category, an overall evidence integration conclusion(s) about the evidence for health effects in humans was drawn by integrating the animal and human evidence synthesis judgments (Section 2.5) and incorporating “other inferences” (see Table 2-43 in Section 2.5), namely the human relevance of the animal evidence (i.e., based on default assumptions or empirical evidence), coherence across the human and animal evidence, and susceptibility. This is summarized in an evidence integration narrative for each health effect in Section 3. As with the evidence synthesis judgments, the overall evidence integration conclusion(s) were reached using decision frameworks adapted from considerations originally described by Austin Bradford Hill (Hill, 1965). During evidence integration, the body of evidence (across evidence streams) was integrated based on a structured framework to draw an overall summary evidence integration judgment regarding the evidence for causation (Table 2-45).

This evidence integration framework is consistent with the IRIS Handbook (U.S. EPA, 2022) and interprets the instructions and examples provided in the cancer guidelines (U.S. EPA, 2005a) to allow clarity and consistency in the evaluation of each potential human hazard. The framework is consistent with the cancer guidelines in that evidence in humans generally has greater weight than evidence in animals. Likewise, in the absence of sufficiently justifiable MOA information, effects in animal models are assumed to be relevant to humans. For potential health hazards where the evidence from animal models influenced the overall evidence integration judgment, the available mechanistic evidence was evaluated to inform the human relevance of those findings in animals.

For each potential health effect evaluated, a narrative evidence integration summary and judgment was developed. The overall evidence integration judgments of evidence demonstrates, evidence indicates [likely], evidence suggests, evidence inadequate (to judge hazard), and strong evidence supports no effect are defined in Table 2-45 and presented as bolded text throughout the assessment, accompanied by a description of the conditions of expression (e.g., exposure levels, exposure patterns) in the studies that served as the basis for the judgment. This is separate from the “sufficient exposure conditions” statements for noncancer health effects that highlight for the reader that the exposure conditions (i.e., levels, duration, timing) for each health outcome identified as a potential human health hazard during evidence integration are further explored and elaborated upon through dose-response analyses (Section 2.7).

Table 2-45 Overall evidence integration judgments for characterizing potential human health hazards (noncancer health effects and cancer outcomes) in the evidence integration narrative

Overall evidence integration judgment in narrative | Explanation and example scenarios
Evidence demonstrates | This signifies a very high level of certainty that formaldehyde exposure causes the health effect in humans.; - This category [underlined: was]^a^ used if there was robust human evidence supporting an effect.; - This category [underlined: could also be] used with moderate human evidence and robust animal evidence if there was strong mechanistic evidence that MOAs and key precursors identified in animals were anticipated to occur and progress in humans.
Evidence indicates (likely) ^b^ | This reflects a reasonable certainty that the relationship between formaldehyde exposure and the health outcome is causal, although there may be some outstanding questions that remain.; - This category [underlined: was] used if there is robust animal evidence supporting an effect and slight-to-indeterminate human evidence, or with moderate human evidence when strong mechanistic evidence was lacking.; - This category [underlined: could] also be used with moderate human evidence supporting an effect and slight or indeterminate animal evidence, or with moderate animal evidence supporting an effect and slight or indeterminate human evidence. In these scenarios, any uncertainties in the moderate evidence were not sufficient to reduce or discount the level of concern, or mechanistic evidence in the slight or indeterminate evidence base (e.g., precursors) existed to increase confidence in the moderate evidence.
Evidence suggests (but is not sufficient to infer) ^c^ | This conveys some concern that formaldehyde may cause a particular health effect in humans, but there were very few studies that contributed to the evaluation, the evidence was very weak or conflicting, or the methodological conduct of the studies was poor. Given the substantial degree of uncertainty, additional research would provide valuable information for future evaluations.; - This category [underlined: was] used if there was slight human evidence and slight-to-indeterminate animal evidence.; - This category [underlined: was] also used with slight animal evidence and slight-to-indeterminate human evidence.; - This category [underlined: could also be] used with moderate human evidence and slight or indeterminate animal evidence, or with moderate animal evidence and slight or indeterminate human evidence. In these scenarios, there were outstanding issues regarding the moderate evidence that reduced the level of concern or confidence in the reliability of the findings, or mechanistic evidence in the slight or indeterminate evidence base (e.g., null results in well-conducted evaluations of precursors) existed to decrease confidence in the moderate evidence.; - Exceptionally, when there is general scientific understanding of mechanistic events that result in a hazard, this category [underlined: could also be] used if there was strong mechanistic evidence that was sufficient to identify a cause for concern—in the absence of adequate conventional studies in humans or in animals (i.e., indeterminate evidence in both).
Evidence inadequate ^d^ | This conveys either a lack of information or an inability to interpret the available evidence.; - This category [underlined: was] used if there was indeterminate human and animal evidence.; - This category [underlined: could also be] used with slight-to-robust animal evidence and indeterminate human evidence if strong mechanistic information indicated that the animal evidence was unlikely to be relevant to humans.; A conclusion of inadequate is not a determination that the agent does not cause adverse health outcomes or is safe. It generally indicates that further research is needed.
Strong evidence supports no effect | This represents a situation in which extensive evidence across a range of populations and exposure levels has identified no effects/associations. This scenario requires a high degree of confidence in the conduct of individual studies, including consideration of study sensitivity, and comprehensive assessments of the endpoints and lifestages of exposure relevant to the heath effect of interest.; - This category [underlined: was] used with compelling evidence of no effect in human studies and compelling evidence of no effect or slight evidence in animal studies.; - This category [underlined: was] also used with indeterminate human evidence and compelling evidence of no effect in animal models concluded to be relevant to humans.; - This category [underlined: could also be] used with compelling evidence of no effect in human studies and moderate-to-robust animal evidence if strong mechanistic information indicates that the animal evidence is unlikely to be relevant to humans.

Note: This table does not supersede or alter direction provided in EPA guidelines. It is meant only to provide added transparency for conclusions drawn regarding the level of evidence from human, animal, and mechanistic studies.

a Terminology of “was” refers to the default option; terminology of “could also be” refers to alternative options.

b For some applications, such as benefit-cost analysis, to better differentiate the categories of evidence demonstrates and evidence indicates (likely), the latter category should be interpreted as evidence that supports an exposure-effect linkage that is likely to be causal.

c Health effects characterized as having evidence demonstrates and evidence indicates (likely) (and, in some cases, evidence suggests) are evaluated for use in dose-response assessment. When the database includes at least one well-conducted study and a judgment of evidence suggests is drawn, quantitative analyses may still be useful for some purposes (e.g., providing a sense of the magnitude and uncertainty of estimates for health effects of potential concern, ranking potential hazards, or setting research priorities), but not for others [see related discussions in U.S. EPA (2005b)]. It is critical to transparently convey the extreme uncertainty in any such estimates.

d Specific narratives for each of the health effects with an evidence integration judgment of evidence inadequate may be deemed unnecessary.

For the purposes of this assessment, the same evidence integration approach was used to draw evidence integration judgments for both noncancer health effects and specific cancer types, noting that the approach is based on the methods and considerations described in the EPA cancer guidelines (U.S. EPA, 2005a). Also consistent with these guidelines, for carcinogenicity, a final step of categorizing the weight of evidence as to whether formaldehyde inhalation exposure is carcinogenic to humans was summarized using “descriptors,” consistent with EPA cancer guidelines (U.S. EPA, 2005a) (Table 2-46). Thus, the descriptors build upon the overall evidence integration judgments for individual cancer types; however, this does not alter or supersede direction provided in EPA guidelines. These descriptors are bolded and italicized throughout the assessment.

Table 2-46 Criteria for applying cancer descriptors to overall confidence conclusions for cancer types

Cancer descriptor | Criteria
Carcinogenic to humans | This descriptor was used if the evidence demonstrates that, for at least one cancer type, formaldehyde inhalation exposure caused the increase in cancer incidence or mortality.; This descriptor could also be used in rare instances if the evidence indicates that formaldehyde inhalation exposure likely causes different cancer types across evidence bases (e.g., when one type of cancer is based on human evidence and tumors at another site is supported by animal evidence), consistent with EPA guidelines (U.S. EPA, 2005a) that site concordance is not required. Such a decision would depend on mechanistic understanding (i.e., in this example, the decision would consider differences in tumor types or ADME across species).
Likely to be carcinogenic to humans | This descriptor was used if the evidence indicates that, for at least one cancer type, formaldehyde inhalation exposure likely caused the increase in cancer incidence or mortality.; Similar to the rationale provided above, this descriptor could also be used in rare instances when the evidence suggests formaldehyde inhalation exposure may cause multiple tumor types, depending on mechanistic inference.
Suggestive evidence of carcinogenic potential | This descriptor was used if, for the evidence relating to carcinogenicity, the evidence was only suggestive that formaldehyde inhalation exposure may cause any of the observed increases in cancer incidence or mortality for any cancer type. This would reflect a substantial degree of uncertainty in any potential causal inference.
Inadequate evidence to assess carcinogenic potential | This descriptor was used if the evidence was inadequate to draw a conclusion regarding cancers of any type with any confidence. This might reflect a lack of information or highly conflicting information.
Not Likely to be carcinogenic to humans | This descriptor conveys a high degree of certainty that there is negligible concern for carcinogenic effects. A substantial amount of evidence would be required to support this descriptor (see (U.S. EPA, 2005a).

## 2.7 DOSE-RESPONSE ASSESSMENT METHODS

This formaldehyde assessment includes development of organ/system-specific RfCs (osRfC) for noncancer health effects identified as human hazards and an overall RfC for noncancer effects, as well as an IUR for carcinogenic effects, all presented in units of μg/m^3^.^14^ The dose-response analyses (Section 5) build from the hazard identification decisions, exploring and better defining the “sufficient exposure conditions” mentioned in Section 3. This highlights that, for those assessment-specific health effects identified as potential hazards, the exposure conditions associated with those health effects are defined (as are the uncertainties in the ability to define those conditions) during dose-response analysis (U.S. EPA, 2022).

Based on the data available for this assessment, the subset of studies used to develop RfCs and inhalation unit risk estimates were from those noncancer health outcomes and specific cancer types with an overall judgment of evidence demonstrates or evidence indicates [likely] regarding the potential for formaldehyde inhalation to cause those effects. For noncancer toxicity values, the dose-response analyses attempt to characterize the exposure conditions (i.e., levels, duration, timing) that are interpreted as “likely to be without an appreciable risk of deleterious effects during a lifetime” in any individual (i.e., RfCs are health-protective values). For cancer toxicity values, the dose-response analysis provides an upper-bound estimate of the increased lifetime risk of cancer from continuous exposure to an agent at a concentration of 1 µg/m^3^ formaldehyde in air.

From among the large body of evidence used for the hazard identification, selection of the studies for dose-response assessment relied first on the study confidence evaluations (i.e., for this extensive evidence base, only high or medium confidence studies were evaluated for potential use in dose-response analyses), with particular emphasis and reconsideration (in the context of utility of the study for dose-response analysis) of expert ratings regarding potential co-exposure and confounding. The characteristics of the study population, details regarding exposure levels, the accuracy of formaldehyde exposure, and the reliability of the outcome measures are also separately reconsidered. In addition, study selection considered factors not necessarily considered during individual study evaluations, including interpretations regarding the severity of the observed effects, potential susceptibility, the study-specific formaldehyde exposure conditions (levels, duration, periodicity), and the utility of the results for quantitative analyses. The considerations for study selection are outlined in Table 2-47. As with the study evaluations (see Section 2.3), the application of these considerations cannot be reduced to a formula and a scoring approach was not used. Rather, for the evaluation of each factor, study-specific limitations interpreted to potentially impact the utility of the study results for dose-response analysis were documented, based on expert judgment. Specifically, considering the context of the other available studies on the effect of interest, limitations interpreted to introduce a “critical concern” with the use of the study data in dose-response analysis resulted in that dataset not being advanced for POD derivation. Less significant limitations interpreted to introduce “some concern” may or may not prevent the dataset from advancing for POD derivation; if advanced, these limitations informed later dose-response decisions (e.g., confidence in the cRfC; see below). The evaluation of these considerations applied to individual medium and high confidence studies for potential use in dose-response analysis is documented in Sections 5.1.1 and 5.2.

Table 2-47 Considerations for study selection for quantification of dose response and derivation of toxicity values

Factor | | Considerations
Study Confidence and Confounding | Study Confidence | For this assessment, studies of low confidence are not considered for quantification. The available high and medium confidence studies are further differentiated on the basis of the study attributes below, as well as the specific limitations identified and their potential impact on dose- response analyses.
Study Confidence and Confounding | Co-exposure and Confounding | Studies with a design (e.g., matching procedures, blocking) or analysis (e.g., covariates or other procedures for statistical adjustment) that adequately address the relevant sources of potential meaningful confounding for a given outcome are preferred. For experimental studies, those with better inhalation exposure quality ratings are preferred and studies interpreted to include potential confounding by methanol are not modeled.
Population or Subjects | | Human studies are typically preferred over animal studies to eliminate interspecies extrapolation uncertainties. Animal studies are considered the studies of primary interest when adequate human studies are not available. For some hazards, studies of particular animal species known to respond similarly to humans would be preferred over studies of other species. Dose-response information for the most susceptible subgroups is also preferred, if appropriate given the other considerations herein and permissible based on the available information.
Exposure | Exposure Measures and Levels | Exposure metrics most relevant to quantifying the effects of lifetime formaldehyde exposure for the health outcome of interest are preferred. Exposures near the range of typical environmental human exposures are preferred. Studies with a broad exposure range and multiple exposure levels are preferred to the extent that they can provide information about the shape of the exposure-response relationship (see (U.S. EPA, 2012), Section 2.1.1) and facilitate extrapolation to more relevant (generally lower) exposures.
Exposure | Exposure Duration and Frequency | When developing the (lifetime) RfC, chronic or subchronic studies are preferred over studies of acute exposure durations. Exceptions exist, such as when a susceptible population or lifestage is more sensitive in a particular time window (e.g., developmental exposure). Likewise, studies reflecting formaldehyde exposures most relevant to constant, lifetime exposure (e.g., of a given periodicity or frequency) are prioritized.
Outcome Measure(s) | | Studies that can reliably distinguish the presence or absence of the outcome are preferred. Outcome ascertainment methods using generally accepted or standardized approaches are preferred. Among several relevant health outcomes, preference is generally given to those outcomes that better represent the identified hazard (e.g., more apical, or translatable [to human disease] outcomes are generally preferred), and outcomes interpreted to have greater biological significance or severity. Studies with sufficient latency for measuring the outcome of interest are also preferred.
Results Utility | Study Size and Design | Preference is given to studies using designs expected to have power (e.g., considering sample size or number of cases) to detect responses of suitable magnitude. This does not mean that studies with substantial responses, but low power would be ignored, but that they should be interpreted in light of a confidence interval or variance for the response. Studies that address changes in the number at risk (e.g., through decreased survival) are preferred. Experimental studies with evidence of selective reporting and cohort studies with apparent loss to follow up are generally not preferred.
Results Utility | Results Reporting | Reasonably complete reporting of the results of interest is preferred. Studies with risk estimates for multiple exposure levels or regression coefficients per unit of formaldehyde concentration are generally preferred over LOAELs or NOAELs because they provide information about the shape of the concentration-response curve and allow for benchmark dose modeling. Studies with individual-level data are preferred in general. For example, individual-level data allow for the characterization of experimental variability more realistically and to characterize overall incidence of individuals affected by related outcomes.

a A NOAEL/LOAEL approach may also be used in cases when data are not amenable to BMD modeling (e.g., those resulting from incomplete data availability or from a lack of models that can describe the data adequately).

The ubiquitous endogenous presence of formaldehyde in the body can complicate quantitative risk assessment for several reasons. The role of endogenously generated formaldehyde in human diseases is largely unknown. This includes endogenous formaldehyde generated during normal cellular metabolic processes, as well as formaldehyde produced endogenously within cells (e.g., in the liver) as a breakdown product of external exposures to other chemicals, including ingestion of caffeine (Summers et al., 2012; Hohnloser et al., 1980) and methanol-rich foods or beverages, such as fruit-based liquors (Riess et al., 2010). The mode of action by which toxicity at distal sites, such as bone marrow or reproductive tissues, may occur in response to inhalation of formaldehyde over long periods, also is not known. Once formaldehyde is inhaled and interacts with extracellular aqueous matrices such as mucus in nasal passages and is hydrated, the biochemical reactivity of inhaled formaldehyde and endogenous formaldehyde are presumably very similar, given that there are no differences in chemical structure. However, no specific data are available to inform whether there may be differences in interactions with specific extracellular or intracellular macromolecular targets in vivo. While the rate of cellular detoxification of exogenous formaldehyde remains unknown, the production and subsequent detoxification of endogenous formaldehyde appears to be kept under strict control and has been well described (Burgos-Barragan et al., 2017b).

The focus of the assessment is to estimate the risk over background that results from only the exogenous exposure, and the assessment assumes that background incidence of cancer or other health hazards that may potentially be attributed to endogenous formaldehyde is already accounted for in the background incidence. Endogenous formaldehyde might be responsible for some portion of background risks for some health outcomes, particularly when normal detoxification pathways are deficient (Pontel et al., 2015); but that possibility is not the purpose of this review. This assessment does consider and discuss the potential impact of normal levels of endogenous formaldehyde on the penetration and distribution of inhaled formaldehyde, based on dosimetric models ((Schroeter et al., 2014; Campbell Jr et al., 2020); see Sections 3.1, 5.1.2, and 5.2.1). In addition, efforts to incorporate the unknown contribution of endogenous formaldehyde to background cancer incidence in an attempt to bound low-dose human cancer risks from formaldehyde exposure have been published using a measure of internal dose for inhaled formaldehyde. These papers are discussed in Section 5.2.5 and Appendix D.2.4.

For each health effect for which a toxicity value was derived, one or more animal or human studies were determined to be suitable for use in quantitative dose-response assessment and points of departure (PODs) were determined (see Section 5). In some cases, estimates considered information from mechanistic studies. Specifically, for some outcomes (i.e., nasal cancers; noncancer respiratory tract pathology), analyses included efforts to apply dosimetry models estimating the uptake of inhaled formaldehyde, including an evaluation of modeling efforts to account for the potential contribution of endogenous formaldehyde on uptake. Study-specific PODs were adjusted as appropriate (e.g., for constant, lifetime exposure) and used to calculate candidate toxicity values. For noncancer analyses, cRfCs for were calculated for each potential health effect and one or more cRfCs were selected to represent the osRfC for that effect. For cancer analyses, cancer type-specific unit risks were estimated and, for one mechanism that contributes to cancer risk and appears to involve a threshold, cRfCs were derived. IURs addressing cancers shown to operate through a mutagenic MOA include application of age-dependent adjustment factors (ADAFs), consistent with EPA cancer guideline recommendations to address early life cancer risk (U.S. EPA, 2005b). The strengths and limitations of each estimate are described, and the associated uncertainties are discussed and weighed in selecting the final toxicity values.

A confidence level of high, medium, or low (or a combination of two of these) was assigned to each noncancer toxicity value.^15^ This confidence level was determined based on evaluations of several more narrowly defined confidence determinations for each cRfC that address the interpreted accuracy, reliability, and stability of the value (see Table 2-48), each of which is separately documented and justified in Section 5.1. Specifically, the overall confidence classification was primarily based on confidence in the accuracy of the associated POD calculation(s) and the reliability of the studies used to calculate the PODs, the latter of which considers the strength of the evidence for concluding that formaldehyde inhalation results in the study-specific health effects of interest. To a lesser extent, it also considered the interpreted confidence regarding the completeness of the evidence base for each broader health effect category.

Table 2-48 Considerations for confidence in noncancer toxicity values

Factor | Confidence considerations
Confidence in the POD | This reflects a judgment regarding how well the study-specific data are able to estimate the POD (i.e., a NOAEL, LOAEL, or BMCL). For example, a lower level of confidence would be applied to high-concentration studies that required extrapolation far below the lowest tested concentration to estimate a POD. A confidence classification of Low confidence indicates that the POD derived is expected to be appreciably less accurate than Medium or, more so, High confidence classifications.
Confidence in the Study | This confidence classification builds from the individual study evaluation judgments and the interpreted reliability of those studies for use in dose-response analysis laid out in Table 2-47. It considers the appropriateness of the population and study design for use in deriving the value of interest, including an emphasis on considerations related to its generalizability, interpretability (e.g., as an effect representative of the relevant evidence integration judgment), and its ability to address potential susceptibility. A confidence classification of Low confidence means the reliability of the study data for use in deriving the specific value of interest is interpreted as appreciably lower than Medium or, more so, High confidence classifications.
Confidence in the Evidence Base | Although a UF_D_ = 1 was applied to all candidate and selected toxicity values for this assessment given the extensive formaldehyde database and the expectation that additional study wouldn’t substantially lower the selected overall RfC, it is recognized that the evidence databases for the various health effects are not equal. This confidence classification builds from the broader evidence integration judgments and primarily emphasizes the health effect-specific areas where additional research could reduce existing uncertainties. A confidence classification of Low confidence means the degree of certainty regarding the stability of the value to additional study is appreciably lower than Medium or, more so, High confidence classifications.

These confidence judgments were used with other considerations (i.e., the composite UF for each value and the sensitivity of compared values of similar confidence) to inform toxicity value selection. Specifically, confidence in the cRfCs informed selection of the osRfCs, and confidence in the osRfCs informed selection of the RfC. Considering confidence in the relevant osRfC(s) and also the completeness of the formaldehyde literature database overall, an overall level of confidence in the RfC was drawn. For noncancer dose-response analyses, multiple graphical depictions were developed to display PODs, uncertainty factors, and candidate toxicity values across outcomes and studies, as well as the context of these estimates (e.g., in relation to the study-specific results; in relation to known human exposures to formaldehyde).

For the derivation of the cancer inhalation unit risk (IUR) estimate, an overall level of confidence was assigned as described in the EPA cancer guidelines (U.S. EPA, 2005a).

3 For screening of studies on a few topics (i.e., formaldehyde exposure; toxicokinetics; mechanisms of carcinogenesis), a PECO-based screening approach was not systematically applied or documented for searches through 2016, consistent with the state of practice at that time.

4 Bronchoalveolar lavage (BAL) is a less invasive procedure to evaluate pathology in the lungs. Studies that reported endpoints of injury using BAL were identified and are discussed in the section on mechanisms related to inflammation and immune responses (Section 2.2.6).

5 Studies suggesting that health effects might result from reduced function of enzymes responsible for clearing formaldehyde from relevant tissues (e.g., downregulated ALDH2 in the brain (Tan et al., 2018; Ai L, 2019)), highlight an area of interest for future studies on potential susceptibility to inhaled formaldehyde.

6 A couple’s probability of conception in one menstrual cycle.

7 For genotoxicity, a consistent set of search terms was applied within electronic databases (i.e., PubMed and Web of Science) as outlined in Section 2.2.1. These terms (see Appendix B.2.10) were developed considering the broader topic of mode of action for either respiratory tract or LHP cancers and the retrieved citations were screened for studies on genotoxic endpoints. Like other searches, this was augmented by review of references in prior draft and final national and international health assessments of formaldehyde.

8 The evaluation of each study involved an initial review by a primary topic-specific expert and a secondary review by a second expert who also reviewed the extracted domain-specific details for accuracy (i.e., the secondary reviewer was not blinded to the primary review). Disagreements across the two reviewers were addressed through discussion, with a third reviewer added to address any disagreements that could not be resolved. Only the final domain judgments and classifications were documented. In addition, the discipline-specific experts (e.g., epidemiologists) conducting the evaluations met to discuss judgments on studies across health effects to ensure consistency in the judgments.

9 Note that this criterion applies specifically to formaldehyde and the conditions examined in this review; the relevant exposure range for other exposures or conditions could be very different.

10 Dr. Hasan Arshad, University of Southampton, Southamptom, United Kingdom; Dr. Peter Gergen, National Institute of Allergy and Infectious Diseases, Bethesda, Maryland; Dr. Elizabeth Matsui, Johns Hopkins University, Baltimore, Maryland; Dr. Dan Norbäck, Uppsala University, Uppsala, Sweden; Dr. Matthew Perzanowski, Columbia University, New York City, NY.

11 Dr. Lara Akinbami, U.S. Centers for Disease Control, Atlanta, Georgia; Dr. Peter Gergen, National Institute of Allergy and Infectious Diseases, Bethesda, Maryland; Dr. Christine Joseph, University of Michigan, Ann Arbor, Michigan; Dr. Felicia Rabito, Tulane University, New Orleans, Louisiana; Dr. Carl-Gustaf Bornehag, Karlstad University, Karlstad, Sweden.

12 Even though methanol levels in the air using the generation methods in the other available formalin studies may be quite different, and possibly significantly higher, than the levels estimated by Kamata et al. (1997), given the relative insensitivity of the URT to methanol, these crude comparisons were considered sufficient for interpretations drawn in the context of these URT effects.

13 Mechanistic event is used in this assessment as a generic term for types of endpoints, which may or may not be required for—or even influence—a mode of action; thus, mechanistic events are not necessarily key events, which are necessary precursor steps (or markers of such) in a mode of action (U.S. EPA, 2005a).

14 Throughout this assessment, a conversion of 1 ppm = 1.23 mg/m^3^ formaldehyde is used.

15 For hyphenated confidence classifications, the order of the terms is used to provide greater transparency in the confidence judgment for the purposes of this assessment, which also aids selection of osRfCs from amongst the available cRfCs and selection of the RfC from amongst the available osRfCs. Specifically, when hyphenated, the first term reflects the confidence category and the second term indicates whether the judgment is closer to a higher or lower confidence category, based on the term used (e.g., Medium-high would reflect a medium confidence judgment that is almost a judgment of high confidence). Confidence judgments are a matter of expert judgment based on the evidence available and it can be difficult to compare confidence classifications across assessments, particularly when developed to inform different decision purposes.